# Appendix D. Reference List of Excluded Studies

## Not relevant

The link between erectile dysfunction and cardiovascular disease. Cardiovasc J S Afr 2006;17(5):277
Drugs for rare diseases: Mixed assessment in Europe. Prescrire Int 2007;16(87):36–42.
The ‘effectiveness’ scale therapeutic outcome of pharmacologic therapies for ED: An international consensus panel report. Zhongguo Nankexue Zazhi 2006;20(1):70–72.
Finasteride and minoxidil for alopecia revisited. Medical Letter on Drugs & Therapeutics 2005;47(1222):95–96.
Duloxetine (Cymbalta) for diabetic neuropathic pain. Medical Letter on Drugs & Therapeutics 2005;47(1215–1216):67–68.
Sildenafil (Revatio) for pulmonary arterial hypertension. Medical Letter on Drugs & Therapeutics 2005;47(1215–1216):65–67.
Japanese Society of Hypertension Guidelines for the Management of Hypertension (JSH 2004). Hypertens Res 2006;29(SUPLL.):S1-S102.
Reply by Authors. Br J Urol 2006;175(6):2367–2368.
Voices and choices: Physician, patient, and partner, and partner perspectives on the management of erectile dysfunction. Br J Sex Med 2006;3(SUPPL. 1):4–9.
Managing the side effects of androgen deprivation therapy. The Journal of Supportive Oncology 2006;4(2):97–98.
Aanestad O, Flink R, Norlen BJ. Interference pattern in perineal muscles: A quantitative electromyographic study in patients before and after transurethral surgery of the prostate. Neurourology & Urodynamics. 1997;16(2):101-109. [pmid: 9042672].
Aasebo U, Gyltnes A, Bremnes R M et al. Reversal of sexual impotence in male patients with chronic obstructive pulmonary disease and hypoxaemia with long term oxygen therapy [abstract]. Eur Respir J Suppl 1993;Supplement. .6 Suppl 17, pp.422S, 1993.
Abascal K, Yarnell E. Increasing vitality with adaptogens: Multifaceted herbs for treating physical and mental stress. Alternative & Complementary Therapies. 2003;9(2):54-60.
Abbou CC, Salomon L, Hoznek A, et al. Laparoscopic radical prostatectomy: preliminary results. Urology. 2000;55(5):630-634. [pmid: 10792066].
Abdo CH. The male sexual quotient: a brief, self-administered questionnaire to assess male sexual satisfaction. Br J Sex Med. 2007;4(2):382-389.
Abdo CH, Oliveira Junior WM, Moreira Junior E, et al. The impact of psychosocial factors on the risk of erectile dysfunction and inhibition of sexual desire in a sample of the Brazilian population. Sao Paulo Med J. 2005;123(1):11-14. [pmid: 15821809].
Aboseif S, Riemer RK, Stackl W, et al. Quantification of prostaglandin E1 receptors in cavernous tissue of men, monkeys and dogs. Urol Int. 1993;50(3):148-152. [pmid: 8465481].
Aboseif S, Shinohara K, Borirakchanyavat S, et al. The effect of cryosurgical ablation of the prostate on erectile function. Br J Urol. 1997;80(6):918-922. [pmid: 9439410].
Aboseif S, Shinohara K, Breza J, et al. Role of penile vascular injury in erectile dysfunction after radical prostatectomy. Br J Urol. 1994;73(1):75-82. [pmid: 8298902].
Abraham NG, Asija A, Drummond G, et al. Heme oxygenase -1 gene therapy: Recent advances and therapeutic applications. Curr Gene Ther. 2007;7(2):89-108. [pmid: 17430129].
Abrahamsson PA, Anderson J, Boccon-Gibod L, et al. Risks and benefits of hormonal manipulation as monotherapy or adjuvant treatment in localised prostate cancer. Eur Urol. 2005;48(6):900-905. [pmid: 16257109].
Abts M, Claus V, Lataster M. Blood pressure control with valsartan and hydrochlorothiazide in clinical practice: The MACHT observational study. Blood Press. 2006;15(SUPPL. 1):27-32. [pmid: 16492613].
Ackerman DL, Greenland S, Bystritsky A, et al. Relationship between early side effects and therapeutic effects of clomipramine therapy in obsessive-compulsive disorder. J Clin Psychopharmacol. 1996;16(4):324-328. [pmid: 8835709].
Adaikan PG, Gauthaman K, Prasad RNV, et al. Proerectile pharmacological effects of Tribulus terrestris extract on the rabbit corpus cavernosum. Ann Acad Med Singapore. 2000;29(1):22-26. [pmid: 10748960].
Adami HO, Baron JA, Rothman KJ. Ethics of a prostate cancer screening trial.[see comment]. [Review] [31 refs]. Lancet. 1994;343(8903):958-960. [pmid: 7512680].
Adamopoulos DA, Nicopoulou SC, Pangalos G, et al. Attitudes of aging Athenians to andropenia and its consequences, and to potential hormone substitution therapy. Aging Male. 1999;2(1):44-52.
Adamopoulos D, Venaki E, Koukkou E, et al. Association of carotene rich diet with hypogonadism in a male athlete. Asian J Androl. 2006;8(4):488-492. [pmid: 16763727].
Adams Henry E, Motsinger Patrice, McAnulty Richard D, et al. Voluntary control of penile tumescence among homosexual and heterosexual subjects. Arch Sex Behav. 1992;21(1):17-31. [pmid: 1546933].
Adams MC, Chalian VS, Rink RC. Congenital dorsal penile curvature: a potential problem of the long phallus.[see comment]. Br J Urol. 1999;161(4):1304-1307.
Ades T, Gansler T, Miller M, et al. PC-SPES: Current evidence and remaining questions. CA: a Cancer Journal for Clinicians. 2001;51(3):199-204. [pmid: 11577497].
Adeyoju AB, Olujohungbe ABK, Morris J, et al. Priapism in sickle-cell disease; incidence, risk factors and complications - An international multicentre study. BJU Int. 2002;90(9):898-902. [pmid: 12460353].
Adimoelja A. Phytochemicals and the breakthrough of traditional herbs in the management of sexual dysfunctions. Int J Androl 2000;23Suppl-4.
Adler LA, Spencer TJ, Milton DR, et al. Long-term, open-label study of the safety and efficacy of atomoxetine in adults with attention-deficit/hyperactivity disorder: an interim analysis. Hillside J Clin Psychiatry. 2005;66(3):294-299.
Adler L, Dietrich A, Reimherr FW, et al. Safety and tolerability of once versus twice daily atomoxetine in adults with ADHD. Ann Clin Psychiatry. 2006;18(2):107-113. [pmid: 16754416].
Adolfsson J. Health-related quality-of-life assessments in patients with advanced cancer of the prostate. Pharmacoeconomics. 2003;21(4):241-247. [pmid: 12600219].
Adolphe A B, Vlachakis N D, Rofman A B et al. Long term evaluation of amlodipine vs hydrochlorothiazide in patients with essential hypertension. INT 1993;J. CLIN. PHARMACOL. RES. 13(4):203–210.
Adrees M, Boran G. Subclinical hypothyroidism. Cpd Bulletin Clinical Biochemistry. 2002;4(3):67-70.
Adsan O, Ozturk B, Cetinkaya M, et al. The value of cavernous body biopsy in evaluating of impotent men. Arch Ital Urol Androl. 1997;69(3):151-153. [pmid: 9234561].
Adshead JM, Stricker PD. Localised prostate cancer questions patients ask. Med Today. 2004;5(9):18-31.
Aggour A, Mostafa H, el-Shawaf H. Evaluation of the role of corpus cavernosum electromyography as a noninvasive diagnostic tool in male erectile dysfunction. International Urology & Nephrology. 1998;30(1):75-79. [pmid: 9569116].
Agmo A, Turi AL, Ellingsen E, et al. Preclinical models of sexual desire: Conceptual and behavioral analyses. Pharmacology, Biochemistry & Behavior. 2004;78(3):379-404.
Agrawal V, Minhas S, Ralph DJ. Venogenic erectile dysfunction in Klippel-Trenaunay syndrome. BJU Int. 2006;97(2):327-328. [pmid: 16430639].
Ahlering TE, Eichel L, Skarecky D. Rapid communication: early potency outcomes with cautery-free neurovascular bundle preservation with robotic laparoscopic radical prostatectomy. J Endourol. 2005;19(6):715-718. [pmid: 16053361].
Ahlering TE, Skarecky D, Borin J. Impact of cautery versus cautery-free preservation of neurovascular bundles on early return of potency. J Endourol. 2006;20(8):586-589. [pmid: 16903820].
Ahmed HU, Shergill IS, Arya M, et al. Management of detrusor-external sphincter dyssynergia. Nature Clinical Practice Urology. 2006;3(7):368-380.
Ahn BO, Kang KK, Ahn GJ, et al. Efficacy of DA-8159, a new PDE5 inhibitor, for inducing penile erection in rabbits with acute spinal cord injury. Int J Impot Res. 2003;15(6):405-411. [pmid: 14671658].
Ahn HS, Lee SW, Yoon SJ, et al. A comparison of colour duplex ultrasonography after transurethral alprostadil and intracavernous alprostadil in the assessment of erectile dysfunction. J Int Med Res. 2004;32(3):317-323. [pmid: 15174226].
Ahuja S, Bivalacqua TJ, Case J, et al. A pilot study demonstrating clinical benefit from intralesional interferon alpha 2B in the treatment of Peyronie's disease. J Androl. 1999;20(4):444-448. [pmid: 10452584].
Aichhorn W, Whitworth AB, Weiss EM, et al. Second-generation antipsychotics: Is there evidence for sex differences in pharmacokinetic and adverse effect profiles?. Drug Saf. 2006;29(7):587-598. [pmid: 16808551].
Aitchison M, Aitchison J, Carter R. Is the penile brachial index a reproducible and useful measurement?. Br J Urol. 1990;66(2):202-204. [pmid: 2390706].
Aizawa K, Hanaoka T, Kasai H, et al. Long-term vardenafil therapy improves hemodynamics in patients with pulmonary hypertension. Hypertens Res. 2006;29(2):123-128. [pmid: 16755146].
Aizenberg D, Sigler M, Zemishlany Z, et al. Lithium and male sexual function in affective patients. Clin Neuropharmacol. 1996;19(6):515-519. [pmid: 8937790].
Aizenberg D, Zemishlany Z, Dorfman-Etrog P, et al. Sexual dysfunction in male schizophrenic patients. Hillside J Clin Psychiatry. 1995;56(4):137-141.
Akakura K, Suzuki H, Ichikawa T, et al. A randomized trial comparing radical prostatectomy plus endocrine therapy versus external beam radiotherapy plus endocrine therapy for locally advanced prostate cancer: results at median follow-up of 102 months. Jpn J Clin Oncol. 2006;36(12):789-793. [pmid: 17082219].
Akduman B, Crawford ED. The PCPT: New Findings, New Insights, and Clinical Implications for the Prevention of Prostate Cancer. European Urology Supplements. 2006;5(9):634-639.
Akkus E, Carrier S, Rehman J, et al. Is colchicine effective in Peyronie's disease? A pilot study. Urology. 1994;44(2):291-295. [pmid: 8048212].
Akkus E, Iscimen A, Tasli L, et al. Paraffinoma and ulcer of the external genitalia after self-injection of vaseline. Br J Sex Med. 2006;3(1):170-172.
Akkus E, Ozkara H, Alici B, et al. Incision and venous patch graft in the surgical treatment of penile curvature in Peyronie's disease. Eur Urol. 2001;40(5):531-536. [pmid: 11752861].
Al Sa'doni HH, Ferro A. S-Nitrosothiols as nitric oxide-donors: Chemistry, biology and possible future therapeutic applications. Curr Med Chem. 2004;11(20):2679-2690. [pmid: 15544469].
al-Abany M, Steineck G, gren Cronqvist AK, et al. Improving the preservation of erectile function after external beam radiation therapy for prostate cancer. Radiotherapy & Oncology. 2000;57(2):201-206. [pmid: 11054524].
Al-Hesayen A, Floras JS, Parker JD. The effects of intravenous sildenafil on hemodynamics and cardiac sympathetic activity in chronic human heart failure. Eur J Heart Fail. 2006;8(8):864-868. [pmid: 16829186].
Al-Rifaei MA, Zaghloul S, Al-Rifaei AM. Bulboprostatic anastomotic urethroplasty with preservation of potency: anatomical study, operative approach and clinical results. Scandinavian Journal of Urology & Nephrology. 2005;39(2):163-168. [pmid: 16019772].
Albaugh JA. Intracavernosal injection algorithm. Urol Nurs. 2006;26(6):449-453. [pmid: 17253079].
Albert M, Tempany CM, Schultz D, et al. Late genitourinary and gastrointestinal toxicity after magnetic resonance image-guided prostate brachytherapy with or without neoadjuvant external beam radiation therapy. Cancer. 2003;98(5):949-954. [pmid: 12942561].
Alderman CP. Developments in psychiatry - 2002. Journal of Pharmacy Practice & Research. 2002;32(1):47-50.
Alexander NJ, Baker E, Kaptein M, et al. Why consider vaginal drug administration?. Fertility & Sterility. 2004;82(1):1-12. [pmid: 15236978].
Alexander WD. The diabetes physician and an assessment and treatment programme for male erectile impotence. Diabet Med. 1990;7(6):540-543. [pmid: 2142058].
Alexianu M, Weiss GH. Radical prostatectomy versus brachytherapy for early-stage prostate cancer. J Endourol. 2000;14(4):325-328. [pmid: 10910147].
Ali RA. Management of diabetic neuropathy. The Malaysian Journal of Medical Science. 2003;10(2):27-30.
Ali ST, Shaikh RN, Siddiqi A. HIV-1 associated neuropathies in males; impotence and penile electrodiagnosis. Acta Neurol Belg. 1994;94(3):194-199. [pmid: 7976225].
Aliaev IuG, Vinarov A Z, Chalyi M E et al. [Causes of erectile dysfunction after transurethral resection of hyperplastic prostate and its prophylaxis]. Urologii[COMBINING LIGATURE LEFT HALF]a[COMBINING LIGATURE RIGHT HALF] (Moscow, Russia : 2005;1999) Issue 3, pp.28–32, 2005 May–Jun.
Alibhai SMH, Gogov S, Allibhai Z. Long-term side effects of androgen deprivation therapy in men with non-metastatic prostate cancer: A systematic literature review. Critical Reviews in Oncology-Hematology. 2006;60(3):201-215.
Alkhayal S, Lehmann V, Thomas P. A simple noninvasive test to detect vascular disease in patients with erectile dysfunction: a novel method. Br J Sex Med. 2006;3(2):331-336.
Allal AS, Bieri S, Brundler MA, et al. Preoperative hyperfractionated radiotherapy for locally advanced rectal cancers: A phase I-II trial. Int J Radiat Oncol Biol Phys. 2002;54(4):1076-1081. [pmid: 12419434].
Allen A, Hollander E. Diagnosis and treatment of obsessive-compulsive disorder. Primary Psychiatry. 2005;12(12):34-42.
Allen RP, Engel RM, Smolev JK, et al. Comparison of duplex ultrasonography and nocturnal penile tumescence in evaluation of impotence.[see comment]. Br J Urol. 1994;151(6):1525-1529.
Althof SE, Dean J, Derogatis LR, et al. Current perspectives on the clinical assessment and diagnosis of female sexual dysfunction and clinical studies of potential therapies: A statement of concern. Br J Sex Med. 2005;2(SUPPL. 3):146-153.
Althof SE, Eid JF, Talley DR, et al. Through the eyes of women: the partners' perspective on tadalafil. Urology. 2006;68(3):631-635. [pmid: 16979701].
Althof SE, Levine SB, Corty EW, et al. A double-blind crossover trial of clomipramine for rapid ejaculation in 15 couples. Hillside J Clin Psychiatry. 1995;56(9):402-407.
Althof SE, O'Leary MP, Cappelleri JC, et al. Impact of erectile dysfunction on confidence, self-esteem and relationship satisfaction after 9 months of sildenafil citrate treatment. Br J Urol. 2006;176(5):2132-2137.
Althof SE, Rosen RC, DeRogatis L, et al. Outcome measurement in female sexual dysfunction clinical trials: review and recommendations. [Review] [25 refs]. J Sex Marital Ther. 2005;31(2):153-166. [pmid: 15859374].
Althof SE, Turner LA, Levine SB, et al. Through the eyes of women: the sexual and psychological responses of women to their partner's treatment with self-injection or external vacuum therapy. Br J Urol. 1992;147(4):1024-1027.
Althof S, Dean J, Fitzpatrick J, et al. Could urological questionnaires completely replace physiological testing?. BJU Int. 2005;96(9):1210-1212. [pmid: 16287429].
Althof Stanley E. Erectile dysfunction: Psychotherapy with men and couples. Leiblum, Sandra R (Ed); Rosen, Raymond C (Ed) 2000;(2000):514
Althof Stanley E. New roles for mental health clinicians in the treatment of erectile dysfunction. Journal of Sex Education & Therapy. 1998;23(3):229-231.
Althof Stanley E. The Psychology of Premature Ejaculation: Therapies and Consequences. [References]. Br J Sex Med. 2006;3(Suppl 4):324-331.
Althof Stanley E, O'Leary, Michael P, et al. Self-Esteem, Confidence, and Relationships in Men Treated with Sildenafil Citrate for Erectile Dysfunction. [References]. J Gen Intern Med. 2006;21(10):1069-1074. [pmid: 16836626].
Altinkilic B, Hauck EW, Weidner W. Evaluation of penile perfusion by color-coded duplex sonography in the management of erectile dysfunction. [Review] [23 refs]. World J Urol. 2004;22(5):361-364. [pmid: 15672279].
Alvarenga Tathiana AF, Andersen Monica L, Papale Ligia A, et al. Effects of long-term food restriction on genital reflexes in paradoxically sleep-deprived male rats. [References]. Brain Res. 2006;1115(1):148-154. [pmid: 16938279].
Ameda K, Kakizaki H, Koyanagi T, et al. The long-term voiding function and sexual function after pelvic nerve-sparing radical surgery for rectal cancer. Int J Urol. 2005;12(3):256-263. [pmid: 15828952].
Amr MM, Abbas EZ, El-Samra M, et al. Neuropsychiatric syndromes and occupational exposure to zinc phosphide in Egypt. Environ Res. 1997;73(12):200-206. [pmid: 9311548].
Anafarta K, Aydos K, Yaman O. Is deep dorsal vein arterialization an alternative surgical approach to treat venogenic impotence?. Urol Int. 1997;59(2):109-112. [pmid: 9392058].
Anafarta K, Yaman O, Aydos K. Clinical experience with Dynaflex penile prostheses in 120 patients. Urology. 1998;52(6):1098-1100. [pmid: 9836562].
Anantharaman P, Schmidt RJ. Sexual function in chronic kidney disease. Adv Chronic Kidney Dis. 2007;14(2):119-125. [pmid: 17395114].
Anastasiadis AG, Benson MC, Rosenwasser MP, et al. Cavernous nerve graft reconstruction during radical prostatectomy or radical cystectomy: safe and technically feasible. Prostate Cancer & Prostatic Diseases. 2003;6(1):56-60. [pmid: 12664067].
Anastasiadis AG, Ghafar MA, Burchardt M, et al. Economic aspects of medical erectile dysfunction therapies. Expert Opin Pharmacother. 2002;3(3):257-263. [pmid: 11866676].
Anastasiadis AG, Salomon L, Katz R, et al. Radical retropubic versus laparoscopic prostatectomy: a prospective comparison of functional outcome. Urology. 2003;62(2):292-297. [pmid: 12893338].
Andersen ML, Tufik SEM. Inhibitory effect of GABAergic drugs in cocaine-induced genital reflexes in paradoxical sleep-deprived male rats. [References]. Pharmacology, Biochemistry and Behavior. 2004;78(2):301-307.
Andersen ML, D'Almeida V, Martins PJF, et al. Effects of paradoxical sleep deprivation and cocaine on genital reflexes in hyperlipidic-fed rats. Pharmacology, Biochemistry & Behavior. 2005;81(4):758-763.
Andersen ML, Perry JC, Battisti MC, et al. Association of paradoxical sleep deprivation and ecstasy (MDMA) enhances genital reflexes in male rats. [References]. Behav Brain Res. 2006;170(2):287-292. [pmid: 16621058].
Andersen Monica L, Tufik Sergio, et al. The effects of dopaminergic agonists on genital reflexes in paradoxical sleep deprived male rats. [References]. Physiol Behav. 2005;84(2):205-210. [pmid: 15708772].
Andersen Monica L, Antunes Isabela B, Tufik Sergio, et al. Effects of paradoxical sleep deprivation on genital reflexes in five rat strains. [References]. Horm Behav. 2006;49(2):173-180. [pmid: 16005458].
Andersen Monica L, Bignotto Magda, Tufik Sergio, et al. The effect of apomorphine on genital reflexes in male rats deprived of paradoxical sleep. [References]. Physiol Behav. 2003;80(23):211-215. [pmid: 14637218].
Andersen Monica, Levy Bignotto, Magda Sergio, et al. Influence of paradoxical sleep deprivation and cocaine on development of spontaneous penile reflexes in rats of different ages. [References]. Brain Res. 2003;968(1):130-138. [pmid: 12644271].
Anderson Monica L, Bignotto Magda, Tufik Sergio, et al. Cocaine-induced genital reflexes during paradoxical sleep deprivation and recovery. [References]. Physiol Behav. 2003;78(2):255-259. [pmid: 12576123].
Anderson RB, Testa MA. Symptom distress checklists as a component of quality of life measurement: Comparing prompted reports by patient and physician with concurrent adverse event reports via the physician. Drug Inf J. 1994;J. 28(1):89-114.
Anderson RU, Wise D, Sawyer T, et al. Sexual Dysfunction in Men With Chronic Prostatitis/Chronic Pelvic Pain Syndrome: Improvement After Trigger Point Release and Paradoxical Relaxation Training. Br J Urol. 2006;176(4):1534-1539.
Anderson TR, Goldberg JF, Harrow M. A review of medication side effects and treatment adherence in bipolar disorder. Primary Psychiatry. 2004;11(9):48-54.
Andersson KE, Stief CG. Neurotransmission and the contraction and relaxation of penile erectile tissues. World J Urol. 1997;15(1):14-20. [pmid: 9066089].
Andersson KE, Schroder A. Therapeutic strategies for drug treatment of stress urinary incontinence. Drug Discovery Today: Therapeutic Strategies. 2004;1(2):259-265.
Andersson KE, Hedlund P, Nehra Porst, et al. New directions for erectile dysfunction therapies. Int J Impot Res. 2002;14(SUPPL. 1):S82-S92. [pmid: 11850740].
Andersson KE, Mulhall JP, Wyllie MG. Pharmacokinetic and pharmacodynamic features of dapoxetine, a novel drug for ‘on-demand’ treatment of premature ejaculation. BJU Int. 2006;97(2):311-315. [pmid: 16430636].
Andolfi Maurizio, Haber Russell. Please help me with this family: Using consultants as resources in family therapy. (1994) 1994;xvii, 294 pp. Philadelphia, PA, US294
Andresen R, Wegner HEH, Miller K, et al. An intrapersonal comparison of ultrasound sonography, X-ray in mammography technique, computerized tomograpby, and nuclear magnetic resonance in 20 patients. Eur Urol. 1998;34(2):128-135. [pmid: 9693248].
Anegon M, Esteban J, Jimenez-Garcia R, et al. A postmarketing, open-label study to evaluate the tolerability and effectiveness of replacing standard-formulation doxazosin with doxazosin in the gastrointestinal therapeutic system formulation in adult patients with hypertension. Clin Ther. 2002;24(5):786-797. [pmid: 12075946].
Anghelescu Ion, Urbanek Carsten, et al. Tadalafil in a Patient With Treatment-Resistant Depression and Antidepressant Polypharmacy. [References]. J Clin Psychopharmacol. 2005;25(2):191-192. [pmid: 15738756].
Angulo J, Bischoff E, Gabancho S, et al. Vardenafil reverses erectile dysfunction induced by paroxetine in rats. Int J Impot Res. 2003;15(2):90-93. [pmid: 12789386].
Angulo J, Cuevas P, Moncada I, et al. Rationale for the combination of PGE(1) and S-nitroso-glutathione to induce relaxation of human penile smooth muscle. Journal of Pharmacology & Experimental Therapeutics. 2000;295(2):586-593. [pmid: 11046092].
Anis Tarek, Shamloul Rany, Ghanem Hussein. Pharmacological treatment of male erectile dysfunction. [References]. Owens, Annette Fuglsang (Ed); Tepper, Mitchell S (Ed) 2007;(2007):419
Annie Potts. The Rise of Viagra: How the Little Blue Pill Changed Sex in America. Men and Masculinities. 2006;9(1):110-112.
Anon Anonymous. Sildenafil: an oral drug for impotence. Med Lett Drugs Ther 1998;40(1026):51–52.
Anonymous. Bashing beta blockers' bad rap. Harv Heart Lett 2002;13(2):7
Anonymous. Love, lust and libido. Diabetes Obes Metab 2001;3(5):381–382.
Anonymous. Goserelin and locally advanced prostate cancer: new indication. Pros and cons. Prescrire Int 2000;9(47):75–76.
Anonymous. PharmaCE Test Questions. Ann Pharmacother 2005;39(7–8):1383–1388.
Anonymous. Weight-loss and regular exercise improves erectile dysfunction in obese men. Evidence-based Healthcare & Public Health 2004;8(6):406–407.
Anonymous. Weight loss may improve erectile function in obese men. Med Today 2004;5(8):10
Anonymous. Vincristine liposomal - INEX: Lipid-encapsulated vincristine, Onco TCS, transmembrane carrier system - Vincristine, vincacine, Vincristine sulfate liposomes for injection, VSLI. Drugs in R & D 2004;5(2):119–123.
Anonymous. New study suggests benefits for insulin detemir. British Journal of Diabetes & Vascular Disease 2003;3(5):381
Anonymous. Phosphodiesterase type 5 (PDE5) inhibitors: Looking beyond erectile dysfunction. British Journal of Cardiology 2003;10(SUPPL. 4):S1-S8.
Anonymous. Custom-made evaluation. Prescrire Int 2003;12(67):195
Anonymous. Treatment for male pattern baldness delays prostate cancer. Hosp Formul 2003;38(9):527
Anonymous. Finasteride and prostate cancer. Med Today 2003;4(9):
Anonymous. Early release of prostate cancer prevention results met with cautionary optimism. Geriatrics and Aging 2003;6(7):11
Anonymous. EGb 761: Ginkgo biloba extract, Ginkor. Drugs in R & D 2003;4(3):188–193.
Anonymous. Early prostate cancer: Surgery versus watchful waiting. Med Today 2002;3(11):10
Anonymous. Surgery & watchful waiting for early prostate cancer provide similar outcomes. Expert Review of Pharmacoeconomics & Outcomes Research 2002;2(5):403–410.
Anonymous. Editor's comment. BJU Int 2002;89(9):i-ii.
Anonymous. News focus. Current Drug Discovery 2002;(pp 15–18):-18.
Anonymous. Cardiovascular effects of sidenafil similar to placebo during exercise. Can Pharm J 2002;268(7185):201
Anonymous. Individual wood construction. Numbered construction kits from Finland. Holz - Kurier 2000;55(33):6
Ansong KS, Lewis C, Jenkins P, et al. Help-seeking decisions among men with impotence. Urology. 1998;52(5):834-837. [pmid: 9801109].
Apfelbaum Bernard. Retarded ejaculation: A much misunderstood syndrome. Leiblum, Sandra R (Ed); Rosen, Raymond C (Ed) 2000;(2000):514
Api M, G÷rgen H, etin A, et al. New diagnostic instrument for sexual function assessment in menopausal women: Libido scoring system. Journal of the Turkish German Gynecology Association Artemis. 2005;6(1):24-29.
Appelhof BC, Brouwer JP, Van Dyck R, et al. Triiodothyronine addition to paroxetine in the treatment of major depressive disorder. Journal of Clinical Endocrinology & Metabolism. 2004;89(12):6271-6276. [pmid: 15579788].
Appelmans Claire, Gill Harcharan, Clerk Alex et al. Medical evaluation of sexual function. Charlton, Randolph S (Ed); Yalom, Irvin D (Ed) 1997;(1997):348-Bass.
Arafa M, Shamloul R. Efficacy of sertraline hydrochloride in treatment of premature ejaculation: A placebo-controlled study using a validated questionnaire. Int J Impot Res. 2006;18(6):534-538. [pmid: 16554853].
Arai Y, Okubo K, Aoki Y, et al. Patient-reported quality of life after radical prostatectomy for prostate cancer. Int J Urol. 1999;6(2):78-86. [pmid: 10226812].
Argiolas Antonio, Melis Maria Rosaria, et al. The role of oxytocin and the paraventricular nucleus in the sexual behaviour of male mammals. [References]. Physiol Behav. 2004;83(2):309-317. [pmid: 15488547].
Argoff CE, Backonja MM, Belgrade MJ, et al. Consensus guidelines: Treatment planning and options. Mayo Clin Proc. 2006;81(4 SUPPL.):S12-S25. [pmid: 16608049].
Ari G, Vardi Y, Finberg JP. Nitric oxide and penile erection in streptozotocin-diabetic rats. Clin Sci. 1999;96(4):365-371. [pmid: 10087243].
Arlt W, Hove U, Muller B, et al. Frequent and frequently overlooked: Treatment-induced endocrine dysfunction in adult long-term survivors of primary brain tumors. Neurology. 1997;49(2):498-506. [pmid: 9270585].
Armagan A, Kim NN, Goldstein I, et al. Dose-response relationship between testosterone and erectile function: evidence for the existence of a critical threshold. J Androl. 2006;27(4):517-526. [pmid: 16582415].
Armenakas NA, McAninch JW, Lue TF, et al. Posttraumatic impotence: magnetic resonance imaging and duplex ultrasound in diagnosis and management. Br J Urol. 1993;149(5 Pt 2):1272-1275.
Armstrong EP, Skrepnek GH, Haim Erder M. Cost-utility comparison of escitalopram and sertraline in the treatment of major depressive disorder. Current Medical Research & Opinion. 2007;23(2):251-258. [pmid: 17288678].
Arrison DP, Cabelin M, Seidmon EJ. Corporoscopic-assisted removal of ruptured inflatable penile prosthesis. Tech Urol. 2001;7(3):249-250. [pmid: 11575524].
Arvanitis L A, Goldstein J M. The Atypical Profile of Quetiapine Is Supported by Its Lack of Sustained Elevation of Plasma Prolactin Concentrations CONFERENCE ABSTRACT. 150th Annual Meeting of the American Psychiatric Association 1997;San Diego, California, USA. 17–22 May,. 1997. 1997.
Ascoli P, Cavagnini F. Hypopituitarism. Pituitary. 2006;9(4):335-342. [pmid: 17077946].
Ashburn TT, Thor KB. Drug repositioning: Identifying and developing new uses for existing drugs. Nat Rev Genet. 2004;3(8):673-683.
Ashraf VV, Taly AB, Nair KP, et al. Role of clinical neurophysiological tests in evaluation of erectile dysfunction in people with spinal cord disorders. Neurol India. 2005;53(1):32-35. [pmid: 15805652].
Ashton AK, D'Mello DA, Dantz B, et al. Treatment regimens for managing depression in family practice. J Fam Pract. 2003;52(SUPPL.):S48-S60. [pmid: 14693078].
Ashworth DM, Batt AR, Baxter AJ, et al. Nonpeptide oxytocin agonists. Drugs of the Future. 2006;31(4):345-353.
Asser Jonathan, et al. Working with prisoners in a transitional space. [References]. Psychodynamic Practice: Individuals, Groups and Organisations. 2002;8(1):7-19.
Astorga R, Cantero O, Contreras D, et al. Intralesional recombinant interferon alpha-2b in Peyronie's disease. Arch Esp Urol. 2000;53(7):665-671. [pmid: 11037665].
Atahan O, Kayigil O, Metin A. Electrical activity of corpus cavernosum in vasculogenic and non-vasculogenic erectile dysfunction. Scandinavian Journal of Urology & Nephrology. 1997;31(6):549-554. [pmid: 9458514].
Atala A, Amin M. Current concepts in the treatment of genitourinary tract disorders in the older individual. [Review] [87 refs]. Drugs Aging. 1991;1(3):176-193. [pmid: 1724398].
Atan A, Basar MM, Aydoganli L. Comparison of the efficacy of fluoxetine alone vs. fluoxetine plus local lidocaine ointment in the treatment of premature ejaculation. Arch Esp Urol. 2000;53(9):856-858. [pmid: 11196396].
Atan A, Delibasi T, Tuncel A. Re: Edoardo Austoni, Vincenzo Mirone, Fabio Parazzini, Ciro Basile Fasolo, Paolo Turchi, Edoardo S. Pescatori, Elena Ricci and Vincenzo Gentile. Smoking as a risk factor for erectile dysfunction: data from the andrology prevention weeks 2001-2002, a study of the italian society of andrology (S.I.A.). Eur Urol 2005;48:810-8. Eur Urol 2006;50(3):625–626.
Ateyah A, El-Nashar AR, Zohdy W, et al. Intracavernosal irrigation by cold saline as a simple method of treating latrogenic prolonged erection. Br J Sex Med. 2005;2(2):248-253.
Aung HH, Dey L, Rand V, et al. Alternative therapies for male and female sexual dysfunction. Am J Chin Med. 2004;32(2):161-173. [pmid: 15315255].
Austoni E, Colombo F, Mantovani F, et al. Venous surgery in erectile dysfunction: Therapeutic strategy and results. Urol Int. 1992;49(1):63-68. [pmid: 1413328].
Authors Kayigil, Ergen A. Caverno-occlusive and autonomic dysfunction: a new concept in young patients. Eur Urol. 1998;34(2):124-127. [pmid: 9693247].
Aversa A, Fabbri A. New oral agents for erectile dysfunction: What is changing in our practice?. Asian J Androl. 2001;3(3):175-179. [pmid: 11561186].
Aversa A, Basciani S, Visca P, et al. Platelet-derived growth factor (PDGF) and PDGF receptors in rat corpus cavernosum: Changes in expression after transient in vivo hypoxia. Rom J Endocrinol. 2001;170(2):395-402.
Aversa A, Bruzziches R, Spera G. Diagnosing erectile dysfunction: the penile dynamic colour duplex ultrasound revisited. [Review] [16 refs]. Int J Androl. 2005;28(Suppl):261-63.
Aversa A, Bruzziches R, Pili M, et al. Phosphodiesterase 5 inhibitors in the treatment of erectile dysfunction. Curr Pharm Des. 2006;12(27):3467-3484. [pmid: 17017940].
Aversano T, Marino PN. Effect of ischemic zone size on nonischemic zone function. American Journal of Physiology - Heart & Circulatory Physiology. 1990;258(6 276):H1786-H1795.
Avram MR, Cole JP, Gandelman M, et al. The potential role of minoxidil in the hair transplantation setting. J Dermatol Surg. 2002;28(10):894-900.
Awwad Z, bu-Hijleh M, Basri S, et al. Penile measurements in normal adult Jordanians and in patients with erectile dysfunction. Int J Impot Res. 2005;17(2):191-195. [pmid: 15510185].
Aydin S, Ercan M, Caskurlu T, et al. Acupuncture and hypnotic suggestions in the treatment of non-organic male sexual dysfunction. Scandinavian Journal of Urology & Nephrology. 1997;31(3):271-274. [pmid: 9249892].
Aydogan S, Bircan MK, Sahin H, et al. The importance of visual erotic stimulation in the differential diagnosis of erectile impotence. International Urology & Nephrology. 1997;29(2):233-235. [pmid: 9241553].
Azad N, Emanuele NV, Abraira C, et al. The effects of intensive glycemic control on neuropathy in the VA cooperative study on type II diabetes mellitus (VA CSDM). Journal of Diabetes & its Complications. 1999;13(56):307-313. [pmid: 10765007].
Azadzoi KM, Schulman RN, Aviram M, et al. Oxidative stress in arteriogenic erectile dysfunction: Prophylactic role of antioxidants. Br J Urol. 2005;174(1):386-393.
Azam U. Late-stage clinical development in lower urogenital targets: sexual dysfunction. [Review] [71 refs]. Br J Pharmacol. 2006;147(Suppl 2):S153-S159. [pmid: 16465180].
Baba K, Yajima M, Carrier S, et al. Delayed testosterone replacement restores nitric oxide synthase-containing nerve fibres and the erectile response in rat penis. BJU Int. 2000;85(7):953-958. [pmid: 10792181].
Babinski MA, Costa WS, Sampaio FJB, et al. Immunohistochemical analysis of smooth muscle cells and volumetric density of the elastic system fibers of wild boar (Sus scrofa) penis. Anim Reprod Sci. 2005;86(34):317-328. [pmid: 15766809].
Bach SP, Mortensen NJM. Revolution and evolution: 30 Years of ileoanal pouch surgery. Inflamm Bowel Dis. 2006;12(2):131-145. [pmid: 16432378].
Badros AZ, Goloubeva O, Rapoport AP, et al. Phase II study of G3139, a Bcl-2 antisense oligonucleotide, in combination with dexamethasone and thalidomide in relapsed multiple myeloma patients. Am J Clin Oncol. 2005;23(18):4089-4099.
Baggott Jonathan, Singh Ashok NE. Sildenafil-induced relapse in bipolar disorder: Is nitric oxide the mechanism? [References]. Int J Neuropsychopharmacol. 2004;7(4):525. [pmid: 15458609].
Bailey Teresa. There is no such thing as an adolescent. [References]. Lanyado, Monica (Ed); Horne, Ann (Ed) 2006;(2006):252
Baker Christine D. A cognitive-behavioural model for the formulation and treatment of sexual dysfunction. Ussher, Jane M (Ed); Baker, Christine D (Ed) 1993;(1993):272
Bakircioglu ME, Lin CS, Fan P, et al. The effect of adeno-associated virus mediated brain derived neurotrophic factor in an animal model of neurogenic impotence. Br J Urol. 2001;165(6 I):2103-2109.
Bakircioglu ME, Sievert KD, Nunes L, et al. Decreased trabecular smooth muscle and caveolin-1 expression in the penile tissue of aged rats. Br J Urol. 2001;166(2):734-738.
Bakris GL, Bell DS, Fonseca V, et al. The rationale and design of the Glycemic Effects in Diabetes Mellitus Carvedilol-Metoprolol Comparison in Hypertensives (GEMINI) trial. J Diabetes Complications. 2005;19(2):74-79. [pmid: 15745836].
Bakris GL, Ferdinand KC, Douglas JG, et al. Optimal treatment of hypertension in African Americans: Reaching and maintaining target blood pressure goals. Postgrad Med. 2002;112(4):73-84. [pmid: 12400150].
Bakshi S, Miller DK. Assessment of the aging man. Med Clin North Am. 1999;83(5):1131-1149. [pmid: 10503057].
Balaraman R. Drugs for urological disorders. Indian J Pharmacol. 2002;34(2):137-138.
Baldinger SL, Yogman MW. Atomoxetine. Hosp Formul. 2003;38(2):85-100.
Baldo Omer, Eardley Ian, et al. Diagnosis and investigation of men with erectile dysfunction. [References]. Journal of Men's Health & Gender. 2005;2(1):79-86.
Baldwin DS. Sexual dysfunction associated with antidepressant drugs. [Review] [96 refs]. Expert Opin Drug Saf. 2004;3(5):457-470. [pmid: 15335301].
Balercia G, Boscaro M, Lombardo F, et al. Sexual symptoms in endocrine diseases: psychosomatic perspectives. Psychother Psychosom. 2007;76(3):134-140. [pmid: 17426412].
Ball RA, Lipton SA, Dreyer EB, et al. Entubulization repair of severed cavernous nerves in the rat resulting in return of erectile function. Br J Urol. 1992;148(1):211-215.
Ball RA, Richie JP, Vickers MA. Microsurgical nerve graft repair of the ablated cavernosal nerves in the rat. J Surg Res. 1992;53(3):280-286. [pmid: 1528054].
Ball TP. Editorial comment. Urology. 2001;57(6):1162.
Balon Richard, et al. Sexual difficulties after traumatic brain injury and ways to deal with it. Depress Anxiety. 2005;22(2):100-101.
Baltaci S, Aydos K, Kosar A, et al. Treating erectile dysfunction with a vacuum tumescence device: a retrospective analysis of acceptance and satisfaction. Br J Urol. 1995;76(6):757-760. [pmid: 8535721].
Bancroft J. The endocrinology of sexual arousal. Rom J Endocrinol. 2005;186(3):411-427.
Bancroft J. A history of sexual medicine in the United Kingdom. Br J Sex Med. 2005;2(4):569-574.
Bancroft J. Effects of alpha-2 blockade on sexual response: Experimental studies with delequamine (RS15385). Int J Impot Res. 2000;12(SUPPL. 1):S64-S69.
Bancroft J. Hormones and human sexual behavior. J Sex Marital Ther. 1984;10(1):3-21. [pmid: 6708115].
Bancroft J. Are the effects of androgens on male sexuality noradrenergically mediated? Some consideration of the human. Neuroscience & Biobehavioral Reviews. 1995;19(2):325-330. [pmid: 7630586].
Bancroft J, Malone N. The clinical assessment of erectile dysfunction: a comparison of nocturnal penile tumescence monitoring and intracavernosal injections. Int J Impot Res. 1995;7(2):123-130. [pmid: 7496441].
Bancroft John. Sexual problems. Clark, David Millar (Ed); Fairburn, Christopher G (Ed) 1997;(1997):437
Bancroft John, Carnes Lori, Janssen Erick, et al. Erectile and Ejaculatory Problems in Gay and Heterosexual Men. [References]. Arch Sex Behav. 2005;34(3):285-297. [pmid: 15971011].
Bancroft John, Herbenick Debra, Barnes Tricia, et al. The relevance of the dual control model to male sexual dysfunction: The Kinsey Institute/BASRT collaborative project. [References]. Sexual and Relationship Therapy. 2005;20(1):13-30.
Bandi G, Rajpurkar A, MacDonald M F et al. Multiple retained needles: An unusual complication of intracavernous self-injection. Urology 2005;65(4):
Bangalore S, Parkar S, Messerli FH. How useful are beta-blockers in cardiovascular disease?. Anadolu Kardiyol Derg. 2006;6(4):358-363. [pmid: 17162285].
Baniel J, Israilov S, Shmueli J, et al. Sexual function in 131 patients with benign prostatic hyperplasia before prostatectomy. Eur Urol. 2000;38(1):53-58. [pmid: 10859442].
Banks Ian, et al. Back to Great Sex. International Journal of Men's Health. 2003;2(3):230-231.
Bannowsky A, Schulze H, van der, et al. Nocturnal Tumescence: A Parameter for Postoperative Erectile Integrity After Nerve Sparing Radical Prostatectomy. Br J Urol. 2006;175(6):2214-2217.
Bar-Chama N, Schiff J, Yavorsky R, et al. Erectile dysfunction and infertility. Current Sexual Health Reports. 2007;4(1):20-23.
Barbaree HE, Mewhort DJ. The effects of the z-score transformation on measures of relative erectile response strength: a re-appraisal. Behaviour Research & Therapy. 1994;32(5):547-558. [pmid: 8042967].
Bari V, Ahmed M N, Rafique M Z et al. Evaluation of erectile dysfunction with color Doppler sonography. 2006;56(6):258–261.
Barkin J, Guimaraes M, Jacobi G, et al. Alpha-blocker therapy can be withdrawn in the majority of men following initial combination therapy with the dual 5a-reductase inhibitor dutasteride. Eur Urol. 2003;44(4):461-466. [pmid: 14499682].
Barkin RL, Barkin S. The role of venlafaxine and duloxetine in the treatment of depression with decremental changes in somatic symptoms of pain, chronic pain, and the pharmacokinetics and clinical considerations of duloxetine pharmacotherapy. Am J Ther. 2005;12(5):431-438. [pmid: 16148429].
Barlow David H. Clinical handbook of psychological disorders: A step-by-step treatment manual (2nd ed.). Refuat Hapeh Vehashinayim 1993;x, 534 pp. New York, NY, US534
Barnes D. How prescription drugs are developed. Australian Prescriber. 2006;29(6):159-161.
Barnes T, Eardley I. Premature ejaculation: The scope of the problem. J Sex Marital Ther. 2007;33(2):151-170. [pmid: 17365515].
Barnett CF, Machado RF. Sildenafil in the treatment of pulmonary hypertension. Vascular Health & Risk Management. 2006;2(4):411-422. [pmid: 17323595].
Barra S, Iacono F. Echo-Doppler-flowmetric assessment of penile dorsal arteries and their role in the erectile mechanism. Eur J Radiol. 1997;25(1):67-73. [pmid: 9248803].
Barreiro P, Soriano V, Gonzalez-Lahoz J, et al. Prevention of nevirapine-associated rash [6]. Lancet. 2001;357(9253):392-393. [pmid: 11211023].
Bartlik B, Goldstein MZ. Maintaining sexual health after menopause. Psychiatr Serv. 2000;51(6):751-753. [pmid: 10828105].
Bartlik Barbara, Goldstein Marion Zucker. Men's sexual health after midlife. [References]. Psychiatr Serv. 2001;52(3):291-293. [pmid: 11239095].
Bartolome SD, Channik RN. Sildenafil for pulmonary arterial hypertension. Future Cardiology. 2006;2(2):137-143. [pmid: 19804069].
Basar MM, Atan A, Tekdogan UY. New concept parameters of RigiScan in differentiation of vascular erectile dysfunction: is it a useful test?. Int J Urol. 2001;8(12):686-691. [pmid: 11851769].
Basar MM, Yildiz M, Basar H, et al. Electrical activity of the corpus cavernosum in denervated rats. Int J Urol. 1999;6(5):251-256. [pmid: 10375188].
Basar M, Basar H, Aydoganli L, et al. Colour penile Doppler ultrasonography with intraurethral prostaglandin-E2: preliminary results. International Urology & Nephrology. 1997;29(6):667-671. [pmid: 9477365].
Bass Barry A. Behavior therapy and the medicalization of male sexuality. [References]. Behavior Therapist. 2002;25(9):167-168.
Bass Barry A. Two positions for sexual intercourse useful in the treatment of male sexual dysfunction. Family Journal: Counseling and Therapy for Couples and Families. 2000;8(4):416-418.
Bass Barry A. In further pursuit of the perfect penis: The comprehensive urology center and the medicalization of male sexual dysfunction. J Sex Marital Ther. 1994;20(4):318-320. [pmid: 7897679].
Bassas L, Ribe N, Rajmil O. Measurement of penile intracavernous pressure with a skin fold caliper. Urol Int. 2004;72(3):225-228. [pmid: 15084767].
Bassiouny HS, Levine LA. Penile duplex sonography in the diagnosis of venogenic impotence. Eur J Vasc Surg. 1991;13(1):75-82.
Basson R, McInnes R, Smith MD, et al. Efficacy and safety of sildenafil citrate im women with sexual dysfunction associated with female sexual arousal disorder. Sexuologie. 2002;9(3):116-124.
Basson R, McInnes R, Smith MD, et al. Efficacy and safety of sildenafil citrate in women with sexual dysfunction associated with female sexual arousal disorder. Journal of Women's Health and Gender-Based Medicine. 2002;11(4):367-377.
Basson Rosemary. Integrating new biomedical treatments into the assessment and management of erectile dysfunction. Can J Hum Sex. 1998;7(3):213-229.
Bates MGD, Thompson AAR, Baillie JK. Phosphodiesterase type 5 inhibitors in the treatment and prevention of high altitude pulmonary edema. Curr Opin Investig Drugs. 2007;8(3):226-231.
Batista JE, Palacio A, Torrubia R, et al. Tamsulosin: effect on quality of life in 2740 patients with lower urinary tract symptoms managed in real-life practice in Spain. Arch Esp Urol. 2002;55(1):97-105. [pmid: 11957763].
Batra AK, Lue TF. The physiology of penile erection. Problems in Urology. 1991;5(4):489-495.
Bauersachs J, Schafer A. Endothelial dysfunction in heart failure: Mechanisms and therapeutic approaches. Current Vascular Pharmacology. 2004;2(2):115-124. [pmid: 15320512].
Bax G, Marin N, Piarulli F, et al. Rigiscan evaluation of specific nervous impairment in patients with diabetes and erectile disorders. Diabetes Care. 1998;21(7):1159-1161. [pmid: 9653612].
Bayes M, Rabasseda X, Prous JR. Gateways to clinical trials. Methods & Findings in Experimental & Clinical Pharmacology. 2006;28(4):233-277. [pmid: 16801985].
bdel-Hamid IA. Phosphodiesterase 5 Inhibitors in Rapid Ejaculation: Potential Use and Possible Mechanisms of Action. Drugs. 2004;64(1):13-26. [pmid: 14723556].
bdel-Hamid IA, Eraky I, Fouda MA, et al. Role of penile vascular insufficiency in erectile dysfunction in renal transplant recipients. Int J Impot Res. 2002;14(1):32-37. [pmid: 11896475].
bdel-Salam Y, Budair Z, Renner C, et al. Treatment of Peyronie's disease by extracorporeal shockwave therapy: evaluation of our preliminary results. J Endourol. 1999;13(8):549-552. [pmid: 10597123].
Beck JG, Bozman AW. Gender differences in sexual desire: the effects of anger and anxiety. Arch Sex Behav. 1995;24(6):595-612. [pmid: 8572909].
Beck-Peccoz P, Persani L. TSH-induced hyperthyroidism caused by a pituitary tumor. Nat Clin Pract Endocrinol Metab. 2006;2(9):524-528. [pmid: 16957766].
Becker AJ, Uckert S, Stief CG, et al. Growth hormone, somatomedins and men's health. Aging Male. 2002;5(4):258-262. [pmid: 12630074].
Becker AJ, Uckert S, Stief CG, et al. Plasma levels of angiotensin II during different penile conditions in the cavernous and systemic blood of healthy men and patients with erectile dysfunction. Urology. 2001;58(5):805-810. [pmid: 11711372].
Becker ME, Hertzberg MA, Moore SD, et al. A placebo-controlled trial of bupropion sr in the treatment of chronic posttraumatic stress disorder. J Clin Psychopharmacol. 2007;27(2):193-197. [pmid: 17414245].
Beckman TJ, Mynderse LA. Evaluation and medical management of benign prostatic hyperplasia. Mayo Clin Proc. 2005;80(10):1356-1362. [pmid: 16212149].
Beckwith Lesli, Jill. Men who seek treatment for erectile disorder at a veteran's administration sexuality clinic: Personality, health locus of control, and sexual functioning. Dissertation Abstracts International: Section B: The Sciences and Engineering 1997;58(5-B):Nov
Bedford SJ, McDonnell SM. Measurements of reproductive function in stallions treated with trimethoprim-sulfamethoxazole and pyrimethamine. J Am Vet Med Assoc. 1999;215(9):1317-1319. [pmid: 10553445].
Befort Christie A. Aspects of health-related quality of life among clinically localized prostate cancer patients. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2005;65(8-B):2005. pp.
Belardinelli R, Lacalaprice F, Faccenda E, et al. Effects of short-term moderate exercise training on sexual function in male patients with chronic stable heart failure. Int J Cardiol. 2005;101(1):83-90. [pmid: 15860388].
Belcaro G, Khan MA, Ledda A, et al. Consensus statement. Current Medical Research & Opinion, Supplement. 1999;16(1):s76-s78.
Beleslin BD, Ostojic M, Djordjevic-Dikic A, et al. Coronary vasodilation without myocardial erection. Simultaneous haemodynamic, echocardiographic and arteriographic findings during adenosine end dipyridamole infusion. Eur Heart J. 1997;18(7):1166-1174. [pmid: 9243152].
Bell A, Davis M, Close F, et al. Sildenafil citrate (revatio) for the treatment of pulmonary arterial hypertension. P & T. 2006;31(3):135-138.
Bella AJ, Brant WO, Brock GB. Contemporary intracavernous pharmacotherapy for erectile dysfunction in the aging male. Aging Health. 2006;2(4):559-570.
Bella AJ, Hayashi N, Carrion RE, et al. FK1706 enhances the recovery of erectile function following bilateral cavernous nerve crush injury in the rat. Br J Sex Med. 2007;4(2):341-346.
Bella AJ, Sener A, Foell K, et al. Nonpalpable scarring of the penile septum as a cause of erectile dysfunction: an atypical form of Peyronie's disease. Br J Sex Med. 2007;4(1):226-230.
Bender AT, Beavo JA. Cyclic nucleotide phosphodiesterases: Molecular regulation to clinical use. Pharmacol Rev. 2006;58(3):488-520. [pmid: 16968949].
Benet AE, Rehman J, Holcomb RG, et al. The correlation between the new RigiScan plus software and the final diagnosis in the evaluation of erectile dysfunction. Br J Urol. 1996;156(6):1947-1950.
Benet AE, Sharaby JS, Melman A. Male erectile dysfunction assessment and treatment options. [Review] [15 refs]. Compr Ther. 1994;20(12):669-673. [pmid: 7882650].
Benson CB, Aruny JE, Vickers MA. Correlation of duplex sonography with arteriography in patients with erectile dysfunction. AJR Am J Roentgenol. 1993;160(1):71-73. [pmid: 8416651].
Bentas W, Wolfram M, Jones J, et al. Robotic technology and the translation of open radical prostatectomy to laparoscopy: the early Frankfurt experience with robotic radical prostatectomy and one year follow-up. Eur Urol. 2003;44(2):175-181. [pmid: 12875935].
Benvenuti F, Boncinelli L, Vignoli GC. Male sexual impotence in diabetes mellitus: vasculogenic versus neurogenic factors. Neurourology & Urodynamics. 1993;12(2):145-151. [pmid: 7920671].
Bereczky Z, Bolus M, Chetty P, et al. Management of benign prostatic hyperplasia - South African urological association guideline. S Afr Med J. 2006;96(12 III):1275-1279. [pmid: 17252159].
Berendsen HHG, Broekkamp CLE. Attenuation of 5-HT(1A) and 5-HT2 but not 5-HT(1C) receptor mediated behaviour in rats following chronic treatment with 5-HT receptor agonists, antagonists or anti-depressants. Psychopharmacology (Berl). 1991;105(2):219-224. [pmid: 1839064].
Berendsen HHG, Jenck F, Broekkamp CLE. Involvement of 5-HT(1C)-receptors in drug-induced penile erections in rats. Psychopharmacology (Berl). 1990;101(1):57-61. [pmid: 2343074].
Berendsen HHG, Kester RCH, Peeters BWMM, et al. Modulation of 5-HT receptor subtype-mediated behaviours by corticosterone. Eur J Pharmacol. 1996;308(2):103-111. [pmid: 8840120].
Berges R. The impact of treatment on lower urinary tract symptoms suggestive of benign prostatic hyperplasia (LUTS/BPH) progression. European Urology Supplements. 2004;3(4):12-17.
Berigan Timothy R, Harazin Jeffrey S. Sexual dysfunction associated with mirtazapine: A case report. Hillside J Clin Psychiatry. 1998;59(6):319-320.
Berkels R, Klotz T, Sticht G, et al. Modulation of human platelet aggregation by the phosphodiesterase type 5 inhibitor sildenafil. J Cardiovasc Pharmacol. 2001;37(4):413-421. [pmid: 11300654].
Berkovitch M, Keresteci AG, Koren G. Efficacy of prilocaine-lidocaine cream in the treatment of premature ejaculation.[see comment]. Br J Urol. 1995;154(4):1360-1361.
Berlant JL. Antiepileptic Treatment of Posttraumatic Stress Disorder. Primary Psychiatry. 2003;10(10):41-49.
Berner M M, Hagen M, Kriston L. Management of sexual dysfunction due to antipsychotic drug therapy. [Review][66 refs]. Cochrane Database Syst Rev 2007;(1):CD003546
Berner MM, Hagen M, Kriston L. A systematic review of research on strategies for the management of antipsychotic-induced sexual dysfunction: high-level evidence is needed. [Review] [21 refs]. Hillside J Clin Psychiatry. 2006;67(10):1649-1650.
Bernstein AJ, Peters KM. Expanding indications for neuromodulation. Urol Clin North Am. 2005;32(1):59-63. [pmid: 15698877].
Berrada S, Kadri N, Mechakra-Tahiri S et al. Prevalence of erectile dysfunction and its correlates: a population-based study in Morocco. Int J Impot Res 2003;15Suppl-7.
Bertaccini A, Marchiori D, Giovannini C, et al. Fibrous hamartoma of corpus cavernosum: A rare cause of congenital penile curvature associated with erectile dysfunction. Br J Urol. 2004;172(2):642-643.
Bertero E, Hallak J, Gromatzky C, et al. Assessment of sexual function in patients undergoing vasectomy using the international index of erectile function. International Braz J Urol. 2005;31(5):452-458. [pmid: 16255791].
Bertol E, Fineschi V, Karch SB, et al. Nymphaea cults in ancient Egypt and the New World: A lesson in empirical pharmacology. J R Soc Med. 2004;97(2):84-85. [pmid: 14749409].
Besharat Mohammad Ali, et al. Management strategies of sexual dysfunctions. Journal of Contemporary Psychotherapy. 2001;31(3):161-180.
Bestmann B, Loetters C, Diemer T, et al. Prostate-specific symptoms of prostate cancer in a German general population. Prostate Cancer & Prostatic Diseases. 2007;10(1):52-59. [pmid: 17102801].
Bethke TD, Bohmer GM, Hermann R, et al. Dose-proportional intraindividual single- and repeated-dose pharmacokinetics of roflumilast, an oral, once-daily phosphodiesterase 4 inhibitor. J Clin Pharmacol. 2007;47(1):26-36. [pmid: 17192499].
Beutel M. Psychosomatic aspects in the diagnosis and treatment of erectile dysfunction. [Review] [40 refs]. Andrologia. 1999;31(Suppl 1):37-44. [pmid: 10643518].
Beyer Carlos, Gonzalez-Mariscal Gabriela. Effects of sex steroids on sensory and motor spinal mechanisms. Psychoneuroendocrinology. 1994;19(57):517-527. [pmid: 7938351].
Bhalerao SS, Solanki NH. Therapeutic approaches to the management of common baldness. Indian Drugs. 2002;39(11):567-573.
Bhargava R, Srivastava DN, Thulkar S, et al. Colour duplex doppler ultrasonography evaluation of non-vasculogenic male erectile dysfunction: An Indian perspective. Australas Radiol. 2002;46(2):170-173. [pmid: 12060156].
Bhasin S, Cunningham GR, Hayes FJ, et al. Testosterone therapy in adult men with androgen deficiency syndromes: an endocrine society clinical practice guideline. Journal of Clinical Endocrinology & Metabolism. 2006;91(6):1995-2010. [pmid: 16720669].
Bhasin S, Enzlin P, Coviello A, et al. Sexual dysfunction in men and women with endocrine disorders. Lancet. 2007;369(9561):597-611. [pmid: 17307107].
Bhasin S, Woodhouse L, Casaburi R, et al. Testosterone dose-response relationships in healthy young men. American Journal of Physiology - Endocrinology & Metabolism. 2001;281(6 446):E1172-E1181. [pmid: 11701431].
Bhatnagar V, Stewart ST, Huynh V, et al. Estimating the risk of long-term erectile, urinary and bowel symptoms resulting from prostate cancer treatment. [Review] [131 refs]. Prostate Cancer & Prostatic Diseases. 2006;9(2):136-146. [pmid: 16402091].
Bhattacharyya A, Tymms DJ, Naqvi N. Asymptomatic pituitary apoplexy after aortocoronary bypass surgery. Int J Clin Pract. 1999;53(5):394-395. [pmid: 10695109].
Bhugra D. Literature update: A critical review. Sexual & Relationship Therapy. 2001;16(1):83-87.
Bhugra D, Crowe M. Physical treatments of erectile disorders. Int Rev Psychiatry. 1995;7(2):217-223.
Bhugra Dinesh, Crowe Michael. Physical treatments of erectile disorders. Int Rev Psychiatry. 1995;7(2):217-223.
Biagiotti G, Cavallini G. Acetyl-L-carnitine vs tamoxifen in the oral therapy of Peyronie's disease: a preliminary report. BJU Int. 2001;88(1):63-67. [pmid: 11446848].
Bialy M, Sachs BD. Androgen implants in medial amygdala briefly maintain noncontact erection in castrated male rats. Hormones & Behavior. 2002;42(3):345-355. [pmid: 12460594].
Bialy Michal, Sachs Benjamin DE. Androgen implants in medial amygdala briefly maintain noncontact erection in castrated male rats. [References]. Horm Behav. 2002;42(3):345-355. [pmid: 12460594].
Bickerton A, Higgins B, Cummings MH. Observational study of ACE inhibitor prescribing habits of diabetes physicians in the UK. Practical Diabetes International. 2003;20(1):21-24.
Biederman J, Spencer TJ. Psychopharmacology of adults with attention-deficit/hyperactivity disorder. Primary Psychiatry. 2004;11(7):57-62.
Biederman J, Wilens TE, Spencer TJ, et al. Diagnosis and treatment of adults with attention-deficit/hyperactivity disorder. CNS Spectr. 2007;12(4 SUPPL. 6):1-14.
Biering-Sorensen F, Sonksen J. Sexual function in spinal cord lesioned men. Proc Annu Clin Spinal Cord Inj Conf. 2001;39(9):455-470.
Bird SJ, Hanno PM. Bulbocavernosus reflex studies and autonomic testing in the diagnosis of erectile dysfunction. J Neurol Sci. 1998;154(1):8-13. [pmid: 9543316].
Birk L. Pharmacotherapy for performance anxiety disorders: Occasionally useful but typically contraindicated. J Clin Psychol. 2004;60(8):867-879. [pmid: 15241814].
Bischoff E. Rabbits as models for impotence research. [Review] [17 refs]. Int J Impot Res. 2001;13(3):146-148. [pmid: 11525311].
Bischoff E, Schneider K. A conscious-rabbit model to study vardenafil hydrochloride and other agents that influence penile erection. Int J Impot Res. 2001;13(4):230-235. [pmid: 11494080].
Bishop JR, Moul JW, Sihelnik SA, et al. Use of glycosylated hemoglobin to identify diabetics at high risk for penile periprosthetic infections. Br J Urol. 1992;147(2):386-388.
Bitner Robert S, Nikkel Arthur L, Otte Stephani, et al. Dopamine D-sub-4 receptor signaling in the rat paraventricular hypothalamic nucleus: Evidence of natural coupling involving immediate early gene induction and mitogen activated protein kinase phosphorylation. [References]. Neuropharmacology. 2006;50(5):521-531. [pmid: 16324724].
Bivalacqua TJ, Burnett AL, Hellstrom WJG, et al. Overexpression of arginase in the aged mouse penis impairs erectile function and decreases eNOS activity: Influence of in vivo gene therapy of anti-arginase. American Journal of Physiology - Heart & Circulatory Physiology. 2007;292(3):H1340-H1351. [pmid: 17071735].
Bivalacqua TJ, Champion HC, Rajasekaran M, et al. Potentiation of erectile response and cAMP accumulation by combination of prostaglandin E1 and rolipram, a selective inhibitor of the type 4 phosphodiesterase (PDE 4). Br J Urol. 1999;162(5):1848-1855.
Bivalacqua TJ, Deng W, Kendirci M, et al. Mesenchymal stem cells alone or ex vivo gene modified with endothelial nitric oxide synthase reverse age-associated erectile dysfunction. American Journal of Physiology - Heart & Circulatory Physiology. 2007;292(3):H1278-H1290. [pmid: 17071732].
Bivalacqua TJ, Usta MF, Kendirci M, et al. Superoxide anion production in the rat penis impairs erectile function in diabetes: influence of in vivo extracellular superoxide dismutase gene therapy. Br J Sex Med. 2005;2(2):187-197.
Bjorklund M. Patterns of morphological variation among cardueline finches (Fringillidae: Carduelinae). Biological Journal - Linnean Society. 1991;43(3):239-248.
Black PC, Friedrich JB, Engrav LH, et al. Meshed unexpanded split-thickness skin grafting for reconstruction of penile skin loss. Br J Urol. 2004;172(3):976-979.
Blake-James B, Attar KH, Emberton M. Treating coexistent benign prostatic hyperplasia/lower urinary tract symptoms and erectile dysfunction in the aging male. Aging Health. 2007;3(2):191-200.
Bland J. Breaking the thought barrier: Musings about placebos and a safer healthcare system. --- 2006;5(2):12–13.
Blanker Marco H, Verhagen Arianne P. Lipid-lowering drugs and erectile dysfunction. [References]. Fam Pract. 2002;19(5):567. [pmid: 12356716].
Blaya C, Seganfredo AC, Dornelles M, et al. The efficacy of milnacipran in panic disorder: An open trial. Int Clin Psychopharmacol. 2007;22(3):153-158. [pmid: 17414741].
Bloomgarden ZT. The European Association for the Study of Diabetes Annual Meeting, 1998: The U.K. Prospective Diabetes Study and other topics in type 2 diabetes. Diabetes Care. 1999;22(6):989-995. [pmid: 10372253].
Boccardo F, Rubagotti A, Barichello M, et al. Bicalutamide monotherapy versus flutamide plus goserelin in prostate cancer patients: results of an Italian Prostate Cancer Project study.[see comment]. Am J Clin Oncol. 1999;17(7):2027-2038.
Bocchio M, Desideri G, Scarpelli P, et al. Endothelial cell activation in men with erectile dysfunction without cardiovascular risk factors and overt vascular damage.[see comment]. Br J Urol. 2004;171(4):1601-1604.
Bocchio M, Scarpelli P, Necozione S, et al. Penile duplex pharmaco-ultrasonography of cavernous arteries in men with erectile dysfunction and generalized atherosclerosis. Int J Androl. 2006;29(4):496-501. [pmid: 16893400].
Bochinski D, Lin GT, Nunes L, et al. The effect of neural embryonic stem cell therapy in a rat model of cavernosal nerve injury. BJU Int. 2004;94(6):904-909. [pmid: 15476533].
Bodansky HJ. Treatment of male erectile dysfunction using the active vacuum assist device. Diabet Med. 1994;11(4):410-412. [pmid: 8088116].
Bodenheimer Carol, Kerrigan Anthony J, Garber Susan L, et al. Sexuality in persons with lower extremity amputations. Disability and Rehabilitation: An International Multidisciplinary Journal. 2000;22(9):409-415.
Bodner DR, Haas CA, Krueger B, et al. Intraurethral alprostadil for treatment of erectile dysfunction in patients with spinal cord injury. Urology. 1999;53(1):199-202. [pmid: 9886612].
Boero R, Rollino C, Massara C, et al. The verapamil versus amlodipine in nondiabetic nephropathies treated with trandolapril (VVANNTT) study. Am J Kidney Dis. 2003;42(1 SUPPL. 2):67-75. [pmid: 12830458].
Boger RH. Asymmetric dimethylarginine (ADMA): A novel risk marker in cardiovascular medicine and beyond. Ann Med. 2006;38(2):126-136. [pmid: 16581698].
Boger RH, Ron ES. L-arginine improves vascular function by overcoming the deleterious effects of ADMA, a novel cardiovascular risk factor. Altern Med Rev. 2005;10(1):14-23. [pmid: 15771559].
Bohart Arthur C. Mr. Lake. Journal of Psychotherapy Integration. 1995;5(2):95-106.
Bokarica P, Parazajder J, Mazuran B, et al. Surgical treatment of Peyronie's disease based on penile length and degree of curvature. Int J Impot Res. 2005;17(2):170-174. [pmid: 15215882].
Bokarica P, Parazajder J, Mazuran B, et al. Selecting the appropriate procedure for Peyronie's disease. The American Journal of Urology Review. 2005;3(2):82-85.
Bolukbasi Okan, Akyol Ali. Spontaneous erections and libido increase associated with venlafaxine. Eur J Neurol. 1999;6(4):527-528. [pmid: 10362913].
Bongale Rajshree N, Tekell Janet L, Haraguchi Gayle E, et al. Continuation of clozapine after priapism. [References]. Am J Psychiatry. 2001;158(12):2087.
Bongers V, Sabin GV. Comparison of the effect of two metoprolol formulations on total ischaemic burden. Clinical Drug Investigation. 1999;17(2):103-110.
Bookstein JJ, Vandeberg J, Machado T. The cavernosal acetylcholine/papaverine response. A practical in vivo method for quantification of endothelium-dependent relaxation: Rationale and experimental validation. Invest Radiol. 1990;25(11):1168-1174. [pmid: 2254052].
Borer JS. Drug insight: If inhibitors as specific heart-rate-reducing agents. Nature Clinical Practice Cardiovascular Medicine. 2004;1(2):103-109.
Borgquist R, Gudmundsson P, Winter R, et al. Erectile dysfunction in healthy subjects predicts reduced coronary flow velocity reserve. Int J Cardiol. 2006;112(2):166-170. [pmid: 16271777].
Borlaug BA, Melenovsky V, Marhin T, et al. Sildenafil inhibits beta-adrenergic-stimulated cardiac contractility in humans. Circulation. 2005;112(17):2642-2649. [pmid: 16246964].
Borrelli-Kerner Sandra, Bernell Bonnie. Couple therapy of sexual disorders. Charlton, Randolph S (Ed); Yalom, Irvin D (Ed) 1997;(1997):348-Bass.
Bortolotti A, Fedele D, Chatenoud L, et al. Cigarette smoking: a risk factor for erectile dysfunction in diabetics. Eur Urol. 2001;40(4):392-396. [pmid: 11713392].
Bortolotti M, Mari C, Lopilato C, et al. Effects of sildenafil on esophageal motility of patients with idiopathic achalasia. Gastroenterology. 2000;118(2):253-257. [pmid: 10648452].
Bosch X. Radiotherapy versus surgery for prostate cancer. Lancet Oncol. 2005;6(5):263. [pmid: 15889497].
Bosshardt RJ, Farwerk R, Sikora R, et al. Objective measurement of the effectiveness, therapeutic success and dynamic mechanisms of the vacuum device. Br J Urol. 1995;75(6):786-791. [pmid: 7613837].
Boswell-Smith V, Spina D, Page CP. Phosphodiesterase inhibitors. Br J Pharmacol. 2006;147(SUPPL. 1):S252-S257. [pmid: 16402111].
Bott SRJ, Birtle A, Kirby RS. The treatment of localised prostate cancer. Mens Health Journal. 2003;2(1):28-31.
Boulton AJM. Current and emerging treatments for the diabetic neuropathies. Diabetes Reviews. 1999;7(4):379-386.
Bourgeois James A, Mundh Harvinder. Priapism associated with risperidone: A case report. [References]. Hillside J Clin Psychiatry. 2003;64(2):218-219.
Boyle P, Robertson C, Mazzetta C, et al. The association between lower urinary tract symptoms and erectile dysfunction in four centres: the UrEpik study. BJU Int. 2003;92(7):719-725. [pmid: 14616454].
Bozman Alan W, Beck J Gayle. Covariation of sexual desire and sexual arousal: The effects of anger and anxiety. Arch Sex Behav. 1991;20(1):47-60. [pmid: 2003771].
Bracarda S, de Cobelli O, Greco C, et al. Cancer of the prostate. Critical Reviews in Oncology-Hematology. 2005;56(3):379-396.
Bradley WE, Farrell DF, Ojemann GA. Human cerebrocortical potentials evoked by stimulation of the dorsal nerve of the penis. Somatosens Mot Res. 1998;15(2):118-127. [pmid: 9730112].
Braithwaite John. Shame and modernity. Br J Criminol. 1993;33(1):1-18.
Brant WO, Bella AJ, Lue TF. Erectile and sexual dysfunction in the aging diabetic male. Aging Health. 2006;2(6):1025-1034.
Bratt G, Stahle L. Sildenafil does not alter nelfinavir pharmacokinetics. Ther Drug Monit. 2003;25(2):240-242. [pmid: 12657921].
Braunstein GD. Endocrine causes of impotence. Optimistic outlook for restoration of potency. Postgrad Med. 1983;74(4):207-217. [pmid: 6622311].
Brawman-Mintzer O, Knapp RG, Rynn M, et al. Sertraline treatment for generalized anxiety disorder: A randomized, double-blind, placebo-controlled study. Hillside J Clin Psychiatry. 2006;67(6):874-881.
Breda G, Xausa D, Puppo P, et al. Urolume in urethral stenosis: Italian Club of Minimally Invasive Urology experience. J Endourol. 1994;8(4):305-309. [pmid: 7981741].
Breiner Sander J E. Male Sexual Dysfunction. [References]. JAMA: Journal of the American Medical Association 2004;292(22):2722-assn.
Bremner AD. Antihypertensive medication and quality of life - Silent treatment of a silent killer?. Cardiovascular Drugs & Therapy. 2002;16(4):353-364. [pmid: 12652105].
Brenner Charles. Discussion. Journal of Clinical Psychoanalysis. 1994;3(3):347-352.
Breza J, Aboseif SR, Lue TF, et al. Cavernous vein arterialization for vasculogenic impotence. An animal model. Urology. 1990;35(6):513-518. [pmid: 2353378].
Brieger Peter. Hypomanic Episodes After Receiving Ziprasidone: An Unintended “On-Off-On” Course of Treatment. [References]. Hillside J Clin Psychiatry. 2004;65(1):132-132.
Brien SE, Heaton JPW, Racz WJ, et al. Effects of an environmental anti-androgen on erectile function in an animal penile erection model. Br J Urol. 2000;163(4):1315-1321.
Briganti A, Montorsi F. Penile rehabilitation after radical prostatectomy. Nature Clinical Practice Urology. 2006;3(8):400-401.
Briganti A, Naspro R, Gallina A, et al. Impact on sexual function of holmium laser enucleation versus transurethral resection of the prostate: results of a prospective, 2-center, randomized trial. Br J Urol. 2006;175(5):1817-1821.
Briganti A, Salonia A, Gallina A, et al. Potency after Radical Prostatectomy: From New Techniques to Better Results. Eau-Ebu Update Series. 2006;4(1):33-45.
Briken P, Hill A, Berner W. Pharmacotherapy of paraphilias with long-acting agonists of luteinizing hormone-releasing hormone: A systematic review. Hillside J Clin Psychiatry. 2003;64(8):890-897.
Briken P, Nika E, Berner W. Treatment of paraphilia with luteinizing hormone-releasing hormone agonists. J Sex Marital Ther. 2001;27(1):45-55. [pmid: 11224953].
Briken Peer, Hill Andreas, Berner Wolfgang. A Relapse in Pedophilic Sex Offending and Subsequent Suicide Attempt During Luteinizing Hormone-Releasing Hormone Treatment. [References]. Hillside J Clin Psychiatry. 2004;65(10):1429.
Brink Nicholas, et al. Dream Wisdom: Uncovering Life's Answers in Your Dreams. [References]. Imagination, Cognition and Personality. 2003;23(23):248-251.
Brink PR, Valiunas V, Wang HZ, et al. Experimental diabetes alters connexin43 derived gap junction permeability in short-term cultures of rat corporeal vascular smooth muscle cells. Br J Urol. 2006;175(1):381-386.
Brioni JD, Moreland RB. Dopamine D4 receptors and the regulation of penile erection. Drug Discovery Today: Therapeutic Strategies. 2006;3(4):599-604.
Brioni JD, Moreland RB, Cowart M, et al. Activation of dopamine D4 receptors by ABT-724 induces penile erection in rats. Proc Natl Acad Sci U S A. 2004;101(17):6758-6763. [pmid: 15087502].
Brock G, Moreira ED, Glasser DB, et al. Sexual disorders and associated help-seeking behaviors in Canada. Can J Urol. 2006;13(1):2953-2961. [pmid: 16515749].
Broderick GA. Changing practice patterns in erectile dysfunction: a diagnostic algorithm for the new millennium. [Review] [42 refs]. Adv Ren Replace Ther. 1999;6(4):314-326. [pmid: 10543711].
Broderick GA, Donatucci CF, Hatzichristou D, et al. Efficacy of tadalafil in men with erectile dysfunction naive to phosphodiesterase 5 inhibitor therapy compared with prior responders to sildenafil citrate. Br J Sex Med. 2006;3(4):668-675.
Broekman CP, Haensel SM, van de V, et al. Bisoprolol and hypertension: effects on sexual functioning in men. J Sex Marital Ther. 1992;18(4):325-331. [pmid: 1291703].
Brookes ST, Donovan JL, Peters TJ, et al. Sexual dysfunction in men after treatment for lower urinary tract symptoms: evidence from randomised controlled trial.[see comment]. BMJ. 2002;324(7345):1059-1061. [pmid: 11991908].
Brooks Gary R, Levant Ronald FE. Is Viagra Enough? Broadening the Conceptual Lens in Sex Therapy with (Heterosexual) Men: A Case Report. [References]. International Journal of Men's Health. 2006;5(2):207-215.
Brophy DF, Ripley EBD, Holdford DA. Pharmacoeconomic considerations in the health system management of anaemia in patients with chronic kidney disease and end stage renal disease. Expert Opin Pharmacother. 2003;4(9):1461-1469. [pmid: 12943475].
Brotons FB, Campos JC, Gonzalez-Correales R, et al. Core document on erectile dysfunction: Key aspects in the care of a patient with erectile dysfunction. Int J Impot Res. 2004;16(SUPPL. 2):S26-S39. [pmid: 15496854].
Brown JA, Rodin D, Lee B, et al. Transperitoneal versus extraperitoneal approach to laparoscopic radical prostatectomy: an assessment of 156 cases. [Review] [13 refs]. Urology. 2005;65(2):320-324. [pmid: 15708046].
Brown Judith, Lichtenberg Philip, Lukensmeyer Carolyn, et al. The implications of Gestalt therapy for social and political change. Gestalt Journal. 1993;16(1):7-54.
Brownell J. Quinagolide (Norprolac(TM)). A novel non-ergot prolactin inhibitor. Med Actual. 1996;32(SUPPL. B):1-31.
Brufsky A, Fontaine-Rothe P, Berlane K, et al. Finasteride and flutamide as potency-sparing androgen-ablative therapy for advanced adenocarcinoma of the prostate. Urology. 1997;49(6):913-920. [pmid: 9187700].
Bruner Deborah, Watkins. Determination of preferences and utilities for the treatment of prostate cancer. (quality of life, treatment utility). Dissertation Abstracts International: Section B: The Sciences and Engineering 2000;60(7-B):Feb
Bryan J. Inhaled products of the modern era: Drugs for non-respiratory conditions. Can Pharm J. 2004;273(7310):161-162.
Bryant JE, Bueschen AJ, Cohn JH, et al. Transurethral prostatectomy: analysis and comparison of four clinical series. South Med J. 1990;83(4):386-389. [pmid: 2181688].
Bschleipfer T, Cimniak HU, Beckert R, et al. Possible hemodynamic pathways of intraurethral prostaglandin-E1 (MUSE). Int J Impot Res. 2004;16(4):365-368. [pmid: 14961055].
Buch JP, Zorn BH, Taylor RJ. Cost-benefit analysis of pharmacologic erection program (PEP) versus penile prosthesis.[comment]. Urology. 1991;37(2):116-118. [pmid: 1899496].
Buddeberg C, Bucher T, Hornung R. [Erectile dysfunction in men in their second half of life]. [German]. Urologe (Ausg 1048;A).(9):1045–1046.
Budia A, Luis Palmero J, Broseta E, et al. Value of semen culture in the diagnosis of chronic bacterial prostatitis: a simplified method. Scandinavian Journal of Urology & Nephrology. 2006;40(4):326-331. [pmid: 16916775].
Buhle Mari Jo. Review of Freud's Free Clinics: Psychoanalysis and Social Justice, 1918-1938. [References]. J Hist Behav Sci. 2006;42(4):401-402.
Bui C, Glassburn J. IMRT for prostate cancer: Improving the therapeutic ratio. Community Oncology. 2006;3(10):659-661.
Bull E. Drug review - Pregabalin. Drugs in Context. 2006;2(2):65-77.
Buller KM, Crane JW, Spencer SJ, et al. Systemic apomorphine alters HPA axis responses to interleukin-1 beta administration but not sound stress. [References]. Psychoneuroendocrinology. 2003;28(6):715-732. [pmid: 12812860].
Bunnell BA, Deng W, Robinson CM, et al. Potential application for mesenchymal stem cells in the treatment of cardiovascular diseases. Canadian Journal of Physiology & Pharmacology. 2005;83(7):529-539. [pmid: 16091779].
Burchardt M, Burchardt T, Anastasiadis AG, et al. Application of angiogenic factors for therapy of erectile dysfunction: protein and DNA transfer of VEGF 165 into the rat penis. Urology. 2005;66(3):665-670. [pmid: 16140112].
Burke JP, Jacobson DJ, McGree ME, et al. Diabetes and sexual dysfunction: results from the Olmsted County study of urinary symptoms and health status among men. Br J Urol. 2007;177(4):1438-1442.
Burke MA, McEvoy JP, Ritchie JC. A pilot study of a structured interview addressing sexual function in men with schizophrenia. Biol Psychiatry. 1994;35(1):32-35. [pmid: 8167201].
Burnett AL. Nitric oxide-based therapy for erectile disorders. Drug Discovery Today: Therapeutic Strategies. 2005;2(1):25-30.
Burnett AL. Pathophysiology of priapism: Dysregulatory erection physiology thesis. Br J Urol. 2003;170(1):26-34.
Burnett AL. Rationale for cavernous nerve restorative therapy to preserve erectile function after radical prostatectomy. Urology. 2003;61(3):491-497. [pmid: 12639630].
Burnett AL. Role of nitric oxide in the physiology of erection. Biol Reprod. 1995;52(3):485-489. [pmid: 7756443].
Burnett AL. Salvage Techniques for Phosphodiesterase 5 Inhibitor Therapy: Purposeful but How Much?. Eur Urol. 2006;50(1):29-30. [pmid: 16567036].
Burnett AL, Lue TF. Neuromodulatory therapy to improve erectile function recovery outcomes after pelvic surgery. [Review] [50 refs]. Br J Urol. 2006;176(3):882-887.
Burnett AL, Allen RP, Davis Wright DC, et al. Near infrared spectrophotometry for the diagnosis of vasculogenic erectile dysfunction. Int J Impot Res. 2000;12(5):247-254. [pmid: 11424961].
Burnett AL, Bivalacqua TJ, Champion HC, et al. Feasibility of the use of phosphodiesterase type 5 inhibitors in a pharmacologic prevention program for recurrent priapism. Br J Sex Med. 2006;3(6):1077-1084.
Burnett AL, Bivalacqua TJ, Champion HC, et al. Long-term oral phosphodiesterase 5 inhibitor therapy alleviates recurrent priapism. Urology. 2006;67(5):1043-1048. [pmid: 16698365].
Burnett AL, Musicki B, Bivalacqua TJ. Molecular science of priapism. Current Sexual Health Reports. 2007;4(1):9-14.
Burnett AL, Musicki B, Jin L, et al. Nitric oxide/redox-based signalling as a therapeutic target for penile disorders. Expert Opin Ther Targets. 2006;10(3):445-457. [pmid: 16706684].
Burnstock G. Purinergic signalling: Therapeutic potential. Anales de la Real Academia Nacional de Farmacia. 2005;71(2):283-319.
Burnstock G. Potential therapeutic targets in the rapidly expanding field of purinergic signalling. Clin Med (Northfield Il). 2002;2(1):45-53.
Burnstock G. Pathophysiology and therapeutic potential of purinergic signaling. Pharmacol Rev. 2006;58(1):58-86. [pmid: 16507883].
Butler RN, Lewis MI, Hoffman E, et al. Love and sex after 60: how to evaluate and treat the impotent older man. A roundtable discussion: Part 2.[see comment]. Geriatrics. 1994;49(10):27-32. [pmid: 7926846].
Buvat J, Bou Jaoude G. Significance of hypogonadism in erectile dysfunction. World J Urol. 2006;24(6):657-667. [pmid: 17082935].
Buyyounouski MK, Horwitz EM, Price RA, et al. Intensity-modulated radiotherapy with MRI simulation to reduce doses received by erectile tissue during prostate cancer treatment. Int J Radiat Oncol Biol Phys. 2004;58(3):743-749. [pmid: 14967429].
Buzelin JM, Fonteyne E, Kontturi M, et al. Comparison of tamsulosin with alfuzosin in the treatment of patients with lower urinary tract symptoms suggestive of bladder outlet obstruction (symptomatic benign prostatic hyperplasia). Br J Urol. 1997;80(4):597-605. [pmid: 9352699].
Byrne RR, Henry GD, Rao DS, et al. Vascular endothelial growth factor restores corporeal smooth muscle function in vitro. Br J Urol. 2001;165(4):1310-1315.
Caballero J, Nahata MC. Atomoxetine Hydrochloride for the Treatment of Attention-Deficit/ Hyperactivity Disorder. Clin Ther. 2003;25(12):3065-3083. [pmid: 14749146].
Cade Brian W. Unpredictability and change: A holographic metaphor. Weeks, Gerald R (Ed) 1991;(1991):325
Cakan M, Yalcinkaya F, Demirel F, et al. Is dorsale penile vein ligation (dpvl) still a treatment option in veno-occlusive dysfunction?. International Urology & Nephrology. 2004;36(3):381-387. [pmid: 15783111].
Calil I, Tineli RA, Vicente WVDA, et al. The concept of crosstalk and its implications for cardiovascular function and disease. Arq Bras Cardiol. 2007;88(1):e25-e30.
Cambio AJ, Evans CP. Outcomes and quality of life issues in the pharmacological management of benign prostatic hyperplasia (BPH). Therapeutics & Clinical Risk Management. 2007;3(1):181-196. [pmid: 18360626].
Campbell BC, Prossinger H, Mbzivo M. Timing of pubertal maturation and the onset of sexual behavior among Zimbabwe school boys. Arch Sex Behav. 2005;34(5):505-516. [pmid: 16211472].
Campbell HE. Clinical monograph for drug formulary review: erectile dysfunction agents. [Review] [64 refs]. Journal of Managed Care Pharmacy. 2005;11(2):151-171. [pmid: 15766322].
Campbell SF. Science, art and drug discovery: a personal perspective. Clin Sci. 2000;99(4):255-260. [pmid: 10995589].
Campling Penelope, et al. Connection and catastrophe, hope and despair in our borderline world. [References]. British Journal of Psychotherapy. 2002;19(2):235-245.
Campo B, Bergamaschi F, Ordesi G, et al. Transurethral needle ablation (TUNA): 1 year of follow-up. Acta Urologica Italica. 1996;10(3):205-207.
Campo C, Segura J, Fernandez ML, et al. A prospective comparison of four antihypertensive agents in daily clinical practice. J Clin Hypertens. 2001;3(3):139-144.
Campos AR, Lima RCP, Uchoa DEA, et al. Pro-erectile effects of an alkaloidal rich fraction from Aspidosperma ulei root bark in mice. J Ethnopharmacol. 2006;104(12):240-244. [pmid: 16229981].
Canada AL, Neese LE, Sui D, et al. Pilot intervention to enhance sexual rehabilitation for couples after treatment for localized prostate carcinoma. Cancer. 2005;104(12):2689-2700. [pmid: 16294343].
Canby-Hagino ED, Brandt TC, Hernandez J, et al. Chemoprevention of prostate cancer with finasteride. Expert Opin Pharmacother. 2006;7(7):899-905. [pmid: 16634712].
Canby-Hagino E, Hernandez J, Brand TC, et al. Looking Back at PCPT: Looking Forward to New Paradigms in Prostate Cancer Screening and Prevention{A figure is presented}. Eur Urol. 2007;51(1):27-33. [pmid: 17030406].
Candela JV, Hellstrom WJ. Three-piece inflatable penile prosthesis implantation: a comparison of the penoscrotal and infrapubic surgical approaches. J La State Med Soc. 1996;148(7):296-301. [pmid: 8816024].
Cantor SB, Spann SJ, Volk RJ, et al. Prostate cancer screening: a decision analysis.[see comment]. J Fam Pract. 1995;41(1):33-41. [pmid: 7798064].
Capaci K, Hepguler S. Comparison of the effects of amitriptyline and paroxetine in the treatment of fibromyalgia syndrome. The Pain Clinic. 2002;14(3):223-228.
Cappelleri JC, Rosen RC. The Sexual Health Inventory for Men (SHIM): A 5-year review of research and clinical experience. Int J Impot Res. 2005;17(4):307-319. [pmid: 15875061].
Cappelleri JC, Rosen RC, Smith MD, et al. Diagnostic evaluation of the erectile function domain of the International Index of Erectile Function. Urology. 1999;54(2):346-351. [pmid: 10443736].
Carbone DJ, Hodges S. Medical therapy for benign prostatic hyperplasia: Sexual dysfunction and impact on quality of life. Int J Impot Res. 2003;15(4):299-306. [pmid: 12934061].
Carbone DJ, Seftel AD. Erectile dysfunction. Diagnosis and treatment in older men. [Review] [33 refs]. Geriatrics. 2002;57(9):18-24. [pmid: 12271825].
Cardinale Vic. The use of a daily diary as a treatment for SSRI-induced sexual dysfunction. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2005;65(9-B):2005. pp.
Caretta N, Ferlin A, Palego PF, et al. Erectile dysfunction in aging men: testosterone role in therapeutic protocols. J Endocrinol Invest. 2005;28(11 Suppl Proceedings):108-111. [pmid: 16760637].
Carey JC. Pharmacological Effects On Sexual Function. Obstetrics & Gynecology Clinics of North America. 2006;33(4):599-620. [pmid: 17116504].
Carey Michael P. Cognitive-behavioral treatment of sexual dysfunctions. Caballo, Vicente E (Ed) 1998;(1998):698
Carey Michael P, Lantinga Larry J, Krauss Dennis J. Male erectile disorder. Hersen, Michel (Ed); Ammerman, Robert T (Ed) 1994;(1994):512
Carlsen JE, Kober L, Torp-Pedersen CT, et al. The optimal dosage of bendrofluazide in hypertension. A randomized double-blind dosage-response investigation. OPTIMAL DOSIS AF BENDROFLUMETIAZID VED HYPERTENSION. EN RANDOMISERET DOBBELTBLIND DOSIS-RESPONSUNDERSOGELSE. UGESKR LAEG. 1990;152(42):3072-3075. [pmid: 2238184].
Carmignani G, Oneto F. Medical therapy of prostate carcinoma. Minerva Urol Nefrol. 2004;56(2):147-163. [pmid: 15195023].
Carraro JC, Raynaud JP, Koch G, et al. Comparison of phytotherapy (Permixon) with finasteride in the treatment of benign prostate hyperplasia: a randomized international study of 1,098 patients. Prostate. 1996;29(4):231-240. [pmid: 8876706].
Carrier S. Pharmacology of phosphodiesterase 5 inhibitors. [Review][21 refs]. Can J Urol 2003;10Suppl-6.
Carrier S. Office-based assessment of the suspected hypogonadal male. Current Sexual Health Reports. 2006;3(1):45-50.
Carrier S, Hricak H, Lee SS, et al. Radiation-induced decrease in nitric oxide synthase—containing nerves in the rat penis. Radiology. 1995;195(1):95-99. [pmid: 7534430].
Carrier S, Zvara P, Lue TF. Erectile dysfunction. Endocrinology & Metabolism Clinics of North America. 1994;23(4):773-782. [pmid: 7705319].
Carson C, Gunn K. Premature ejaculation: Definition and prevalence. Int J Impot Res. 2006;18(SUPPL. 1):S5-S13. [pmid: 16953247].
Carson CC. PDE5 inhibitors: are there differences?. [Review] [27 refs]. Can J Urol. 2006;13(Suppl 1):34-39. [pmid: 16526979].
Carson CC. Combination of phosphodiesterase-5 inhibitors and alpha-blockers in patients with benign prostatic hyperplasia: treatments of lower urinary tract symptoms, erectile dysfunction, or both?. [Review] [21 refs]. BJU Int. 2006;97(Suppl 2):39-43. [pmid: 16507053].
Carson CC. Penile prosthesis implantation: surgical implants in the era of oral medication. [Review] [36 refs]. Urol Clin North Am. 2005;32(4):503-509. [pmid: 16291041].
Carson CC. Cardiac safety in clinical trials of phosphodiesterase 5 inhibitors. [Review] [25 refs]. Am J Cardiol. 2005;96(12B):37M-41M.
Carson CC, Mulcahy JJ, Govier FE. Efficacy, safety and patient satisfaction outcomes of the AMS 700CX inflatable penile prosthesis: results of a long-term multicenter study. AMS 700CX Study Group. Br J Urol. 2000;164(2):376-380.
Carson CC, Porst Nehra, Althof Meuleman. Erectile dysfunction in the 21st century: Whom we can treat, whom we cannot treat and patient education. Int J Impot Res. 2002;14(SUPPL. 1):S29-S34. [pmid: 11850732].
Carson C, Giuliano F, Goldstein I, et al. The ‘effectiveness’ scale—therapeutic outcome of pharmacologic therapies for ED: an international consensus panel report. [Review] [7 refs]. Int J Impot Res. 2004;16(3):207-213. [pmid: 15164088].
Cartledge JJ, Eardley I, Morrison JF. Advanced glycation end-products are responsible for the impairment of corpus cavernosal smooth muscle relaxation seen in diabetes. BJU Int. 2001;87(4):402-407. [pmid: 11251537].
Cartledge J, Minhas S, Eardley I. The role of nitric oxide in penile erection. Expert Opin Pharmacother. 2001;2(1):95-107. [pmid: 11336572].
Carvalho B, Smith M. Viagra(TM): Are anaesthetists rising to the challenge?. Anaesthesia. 2001;56(1):91-93. [pmid: 11167459].
Carver Christi. Premature ejaculation: A common and treatable concern. J Am Psychiatr Nurses Assoc. 1998;4(6):199-204.
Case Trevor I, Williams Kipling D. Ostracism: A Metaphor for Death. [References]. Greenberg, Jeff (Ed); Koole, Sander L (Ed); Pyszczynski, Tom (Ed) 2004;(2004):528
Casey R, Tarride JE, Keresteci MA, et al. The Erectile Function Visual Analog Scale (EF-VAS): a disease-specific utility instrument for the assessment of erectile function. Can J Urol. 2006;13(2):3016-3025. [pmid: 16672112].
Caspari D, Huebgen EM, Derouet H. Interdisciplinary assessment and follow-up of patients with erectile dysfunction - Psychiatric aspects. Int J Impot Res. 1999;11(4):213-217. [pmid: 10467521].
Cassels A, Wright JM, Mintzes B, et al. Direct-to-consumer advertising. Finasteride for male pattern hair loss. Can Fam Physician. 2001;47(SEPT.):1751-1752. [pmid: 11570300].
Catalona WJ. Patient selection for, results of, and impact on tumor resection of potency-sparing radical prostatectomy. Urol Clin North Am. 1990;17(4):819-826. [pmid: 2219579].
Catalona WJ, Carvalhal GF, Mager DE, et al. Potency, continence and complication rates in 1,870 consecutive radical retropubic prostatectomies. Br J Urol. 1999;162(2):433-438.
Catton C, Milosevic M, Warde P, et al. Recurrent prostate cancer following external beam radiotherapy: Follow-up strategies and management. Urol Clin North Am. 2003;30(4):751-763. [pmid: 14680312].
Cavaletti G, Marmiroli P. Chemotherapy-induced peripheral neurotoxicity. Expert Opin Drug Saf. 2004;3(6):535-546. [pmid: 15500413].
Cavalla D. Therapeutic switching: A new strategic approach to enhance R&D productivity. IDrugs. 2005;8(11):914-918. [pmid: 16254785].
Cavalla D. Getting more mileage out of a tankful of new molecular entities?. Drug Discov Today. 2004;9(7):304-305. [pmid: 15037227].
Cavallini G, Biagiotti G, Koverech A, et al. Oral propionyl-l-carnitine and intraplaque verapamil in the therapy of advanced and resistant Peyronie's disease. BJU Int. 2002;89(9):895-900. [pmid: 12010235].
Cavassini ML, D'Acremont V, Furrer H, et al. Pharmacotherapy, vaccines and malaria advice for HIV-infected travellers. Expert Opin Pharmacother. 2005;6(6):891-913. [pmid: 15952919].
Cayan Selahi, tti Bozlu, Murat Canpolat, et al. The assessment of sexual functions in women with male partners complaining of erectile dysfunction: Does treatment of male sexual dysfunction improve female partner's sexual functions? [References]. J Sex Marital Ther. 2004;30(5):333-341. [pmid: 15672601].
Century Gillian, Leavey Gerard, Payne Helen, et al. The experience of working with refugees: Counsellors in primary care. [References]. Br J Guid Counc. 2007;35(1):23-40.
Cetinkaya M, Erdogan E, Adsan O, et al. Evaluation of impotent men with intracorporeal injection of papaverine and colour Doppler ultrasound. International Urology & Nephrology. 1995;27(6):779-782. [pmid: 8725047].
Chahal HS, Drake WM. The endocrine system and ageing. Am J Pathol. 2007;211(2):173-180.
Chahal R, Sundaram SK. Laser ablation of the prostate versus transurethral resection of the prostate in men with benign prostatic hyperplasia [3]. Urology. 2000;56(3):546-547. [pmid: 11001643].
Challem J. Medical journal watch: Context and applications. Alternative & Complementary Therapies. 2006;12(2):102-106.
Champion HC. Erectile dysfunction and cardiovascular disease: Carrots, sticks, and better men's health. Advanced Studies in Medicine. 2006;6(4):163-170.
Champion HC, Bivalacqua TJ, Wang R, et al. [Tyr1]-nociceptin and nociceptin have similar naloxone-insensitive erectile activity in the cat. J Androl. 1998;19(6):747-753. [pmid: 9876026].
Champion HC, Bivalacqua TJ, Wang R, et al. Induction of penile erection by intracavernosal and transurethral administration of novel nitric oxide donors in the cat. Br J Urol. 1999;161(6):2013-2019.
Champion HC, Wang R, Hellstrom WJ, et al. Nociceptin, a novel endogenous ligand for the ORL1 receptor, has potent erectile activity in the cat. Am J Physiol. 1997;273(1 Pt 1):E214-E219. [pmid: 9252499].
Chan DC, Watts GF. Dyslipidemia in the metabolic syndrome. Journal of Drug Evaluation. 2004;2(1):3-34.
Chan NN, Tong PCY, Chan JCN. Management of systemic hypertension: An update for primary care physicians. Hong Kong Practitioner. 2005;27(1):4-14.
Chan SWH, Yung MYP, Que MBW, et al. Adoption of laparoscopic technique for radical prostatectomy in a district hospital in Hong Kong. Annals of the College of Surgeons of Hong Kong. 2004;8(3):83-89.
Chancellor MB, Erhard MJ, Hirsch IH, et al. Prospective evaluation of terazosin for the treatment of autonomic dysreflexia. Br J Urol. 1994;151(1):111-113.
Chancellor MB, Rivas DA, Linsenmeyer T, et al. Multicenter trial in North America of UroLume urinary sphincter prosthesis. Br J Urol. 1994;152(3):924-930.
Chancellor MB, Rivas DA, Panzer DE, et al. Prospective comparison of topical minoxidil to vacuum constriction device and intracorporeal papaverine injection in treatment of erectile dysfunction due to spinal cord injury. Urology. 1994;43(3):365-369. [pmid: 8134992].
Chancellor MB, Tirney S, Mattes CE, et al. Nitric oxide synthase gene transfer for erectile dysfunction in a rat model. BJU Int. 2003;91(7):691-696. [pmid: 12699487].
Chang SW, Fine R, Siegel D, et al. The impact of diuretic therapy on reported sexual function.[see comment]. Arch Intern Med. 1991;151(12):2402-2408. [pmid: 1746997].
Chang S, Hypolite JA, Changolkar A, et al. Increased contractility of diabetic rabbit corpora smooth muscle in response to endothelin is mediated via Rho-kinase beta.[see comment]. Int J Impot Res. 2003;15(1):53-62. [pmid: 12605241].
Chang S, Hypolite JA, Zderic SA, et al. Enhanced force generation by corpus cavernosum smooth muscle in rabbits with partial bladder outlet obstruction. Br J Urol. 2002;167(6):2636-2644.
Chanson P, Brochier S. Non-functioning pituitary adenomas. J Endocrinol Invest. 2005;28(11 Suppl):93-99. [pmid: 16625856].
Chapman AH, Chapman-Santana Mirian. The use of humor in psychotherapy. Arq Neuropsiquiatr. 1995;53(1):153-156. [pmid: 7575201].
Chapple CR. Pharmacological therapy of benign prostatic hyperplasia/lower urinary tract symptoms: An overview for the practising clinician. BJU Int. 2004;94(5):738-744. [pmid: 15329091].
Charlton Randolph S, Brigel Faith W. Treatment of arousal and orgasmic disorders. Charlton, Randolph S (Ed); Yalom, Irvin D (Ed) 1997;(1997):348-Bass.
Chavez ML. PC-SPES for the treatment of prostate cancer?. Journal of Herbal Pharmacotherapy. 2002;2(3):73-89. [pmid: 15277091].
Cheitlin MD. PDE5 inhibitors: Two new drugs and cardiovascular uses beyond erectile dysfunction. Cardiology Review. 2005;22(9):18-22.
Chen HH, Huntley BK, Schirger JA, et al. Maximizing the renal cyclic 3′-5′-guanosine monophosphate system with type V phosphodiesterase inhibition and exogenous natriuretic peptide: A novel strategy to improve renal function in experimental overt heart failure. J Am Soc Nephrol. 2006;17(10):2742-2747. [pmid: 16928803].
Chen J, Chopp M. Neurorestorative Treatment of Stroke: Cell and Pharmacological Approaches. NeuroRx. 2006;3(4):466-473. [pmid: 17012060].
Chen JC, Tao PL, Li JY, et al. Endomorphin-1 and -2 induce naloxone-precipitated withdrawal syndromes in rats. [References]. Peptides. 2003;24(3):477-481. [pmid: 12732348].
Chen J, Greenstein A, Matzkin H. Is a second injection of vasoactive medication necessary during color duplex Doppler evaluation of young patients with veno-occlusive erectile dysfunction?. Urology. 2000;55(6):927-930. [pmid: 10840111].
Chen J, Greenstein A, Sofer M, et al. Rigiscan versus snap gauge band measurements: is the extra cost justifiable?. Int J Impot Res. 1999;11(6):315-318. [pmid: 10637460].
Chen Jack J, Swope David M. A Case of Complex Movement Disorder Induced by Fluoxetine With Management of Dystonia by Botulinum Toxin Type A. [References]. Hillside J Clin Psychiatry. 2005;66(2):267-268.
Chen KK, Chou YH, Chang LS, et al. Sonographic measurement of penile erectile volume. J Clin Ultrasound. 1992;20(4):247-253. [pmid: 1315798].
Chen Y. Acupuncture treatment of functional non-ejaculation: a report of 70 cases. J Trad Chin Med 1993 Mar 1993;13(1):10–12.
Chen Y, Yang R, Yao L, et al. Differential expression of neurotrophins in penises of streptozotocin-induced diabetic rats. J Androl. 2007;28(2):306-312. [pmid: 17079742].
Cheng JL, Hu LQ. Effects of antihypertensive drugs on erectile function and number of nNOS-containing nerve fibers in spontaneously hypertensive rats. Zhonghua Nan Ke Xue. 2003;9(2):115-117. [pmid: 12749131].
Cheng JYW, Ng EML, Ko JSN, et al. Physical activity and erectile dysfunction: Meta-analysis of population-based studies. Int J Impot Res. 2007;19(3):245-252. [pmid: 16929337].
Cherdshewasart W, Nimsakul N. Clinical trial of Butea superba, an alternative herbal treatment for erectile dysfunction. Asian J Androl. 2003;5(3):243-246. [pmid: 12937809].
Chevallier D, Benizri E, Volpq P et al. Peyronie's disease: Review of historical, epidemiologic, and physiopathologic data. Diagnosis and therapeutic approach. Rev Med Interne 1997;18(SUPPL. 1):
Chevlen E. Opioids: A review. Current Pain & Headache Reports. 2003;7(1):15-23. [pmid: 12525266].
Chi KN, Eisenhauer E, Fazli L, et al. A phase I pharmacokinetic and pharmacodynamic study of OGX-011, a 2′-methoxyethyl antisense oligonucleotide to clusterin, in patients with localized prostate cancer. J Natl Cancer Inst. 2005;97(17):1287-1296. [pmid: 16145049].
Chiang HS, Wu CC, Wen TC. 10 years of experience with penile prosthesis implantation in Taiwanese patients. Br J Urol. 2000;163(2):476-480.
Chiang PH, Chiang CP, Wu CC, et al. Colour duplex sonography in the assessment of impotence. Br J Urol. 1991;68(2):181-186. [pmid: 1884147].
Chiariello M. A double-blind comparison of the efficacy and safety of lacidipine and hydrochlorothiazide in essential hypertension. J 1991;CARDIOVASC. PHARMACOL. 17(SUPPL. 4):S35-S37.
Chien GW, Aboseif SR. Corporeal plication for the treatment of congenital penile curvature. Br J Urol. 2003;169(2):599-602.
Chiou RK, Pomeroy BD, Chen WS, et al. Hemodynamic patterns of pharmacologically induced erection: evaluation by color Doppler sonography.[see comment]. Br J Urol. 1998;159(1):109-112.
Chitaley K, Webb RC, Dorrance AM, et al. Decreased penile erection in DOCA-salt and stroke prone-spontaneously hypertensive rats. Int J Impot Res. 2001;13(Suppl 5):S16-S20. [pmid: 11781742].
Choi HK, Choi YJ, Choi YD, et al. SS-Penogram: A new diagnostic test for erectile dysfunction. Yonsei Med J. 2002;43(1):1-6. [pmid: 11854924].
Choi HK, Seong DH, Rha KH. Clinical efficacy of Korean red ginseng for erectile dysfunction. Int J Impot Res. 1995;7(3):181-186. [pmid: 8750052].
Choi S, O'Connell L, Min K, et al. Efficacy of vardenafil and sildenafil in facilitating penile erection in an animal model. J Androl. 2002;23(3):332-337. [pmid: 12002434].
Chong ST, Beasley HS, Daffner RH. POEMS syndrome: Radiographic appearance with MRI correlation. Skeletal Radiol. 2006;35(9):690-695. [pmid: 16247640].
Chow SC, Shao J, Ho HT. On statistical analysis for placebo-challenging designs in clinical trials. Stat Med. 2000;19(8):1029-1037. [pmid: 10790678].
Chowdhury AN, Mukherjee A, Ghosh K, et al. Horizon of a new hope: Recovery of schizophrenia in India. Med Sci Monit. 1999;6(3):181-185.
Choy DSJ. Percutaneous laser disc decompression: An update. Photomedicine and Laser Surgery. 2004;22(5):393-406. [pmid: 15671712].
Chrisofos M, Papatsoris AG, Dellis A, et al. Can prostate biopsies affect erectile function?. Andrologia. 2006;38(3):79-83. [pmid: 16669915].
Christ GJ, Rehman J, Day N, et al. Intracorporal injection of hSlo cDNA in rats produces physiologically relevant alterations in penile function. Am J Physiol. 1998;275(2 Pt 2):H600-H608. [pmid: 9683449].
Christian KA, Griffiths AD, Bedford G, et al. Androgen concentrations and behavior of frillneck lizards (Chlamydosaurus kingii). Journal of Herpetology. 1999;33(1):12-17.
Christman AK, Fermo JD, Markowitz JS. Atomoxetine, a novel treatment for attention-deficit-hyperactivity disorder. Pharmacotherapy. 2004;24(8):1020-1036. [pmid: 15338851].
Chrubasik S, Model A, Black A, et al. A randomized double-blind pilot study comparing Doloteffin and Vioxx in the treatment of low back pain. Rheumatology. 2003;42(1):141-148. [pmid: 12509627].
Chu NV, Edelman SV. Erectile dysfunction and diabetes. [Review] [32 refs]. Curr Diab Rep. 2002;2(1):60-66. [pmid: 12643124].
Chueh SC, Yu HJ, Chiu TY, et al. Treating benign prostatic hyperplasia with finasteride in Chinese men: one-year experience. J Formos Med Assoc. 1996;95(8):650-652. [pmid: 8870441].
Chung BH, Hong SJ. Long-term follow-up study to evaluate the efficacy and safety of the doxazosin gastrointestinal therapeutic system in patients with benign prostatic hyperplasia with or without concomitant hypertension. BJU Int. 2006;97(1):90-95. [pmid: 16336335].
Chung WS, Choi HK. Erotic erection versus nocturnal erection.[see comment]. Br J Urol. 1990;143(2):294-297.
Chung WS, Nehra A, Jacobson DJ, et al. Lower urinary tract symptoms and sexual dysfunction in community-dwelling men. Mayo Clin Proc. 2004;79(6):745-749. [pmid: 15182088].
Chung WS, Park YY, Kwon SW. The impact of aging on penile hemodynamics in normal responders to pharmacological injection: a Doppler sonographic study.[see comment]. Br J Urol. 1997;157(6):2129-2131.
Chung WS, Shim BS, Park YY. Hemodynamic insult by vascular risk factors and pharmacologic erection in men with erectile dysfunction: Doppler sonography study. World J Urol. 2000;18(6):427-430. [pmid: 11204263].
Chung WS, Sohn JH, Park YY. Is obesity an underlying factor in erectile dysfunction?. Eur Urol. 1999;36(1):68-70. [pmid: 10364658].
Churchill BM, van Savage JG, Khoury AE, et al. The dartos flap as an adjunct in preventing urethrocutaneous fistulas in repeat hypospadias surgery. Br J Urol. 1996;156(6):2047-2049.
Chye PL. Alternatives for non-PDE5-I responders in erectile dysfunction patients. Int Surg. 2006;91(5 Suppl):S95-102. [pmid: 17436611].
Ciancio SJ, Kim ED. Penile fibrotic changes after radical retropubic prostatectomy. BJU Int. 2000;85(1):101-106. [pmid: 10619955].
Cilotti A, Forti G, Maggi M. Modulation of penile smooth muscle cells contractility. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):44-49.
Cioanta I, Muschter R. Water-induced thermotherapy for benign prostatic hyperplasia. Tech Urol. 2000;6(4):294-299. [pmid: 11108569].
Cirino G, Fusco F, Imbimbo C, et al. Pharmacology of erectile dysfunction in man. Pharmacol Ther. 2006;111(2):400-423. [pmid: 16443277].
Cisternino M. Omeprazole 20mg uid and ranitidine 150mg bid in the treatment of benign gastric ulcer. Hepatogastroenterology. 1991;38(5):400-403. [pmid: 1765356].
Claes H, Baert L. Pelvic floor exercise versus surgery in the treatment of impotence. Br J Urol. 1993;71(1):52-57. [pmid: 8435738].
Clark JA, Wray NP, Ashton CM. Living with treatment decisions: regrets and quality of life among men treated for metastatic prostate cancer. Am J Clin Oncol. 2001;19(1):72-80.
Clark P E, Torti F M. Prostate Cancer and Bone Metastases: Medical Treatment. Clinical Orthopaedics & Related Research 2003;(pp S148-S157):-S157.
Clayton AH. Female sexual dysfunctions: What controversy?. Hillside J Clin Psychiatry. 2006;67(6):991-992.
Cohan P, Korenman SG. Commentary: Erectile dysfunction. Journal of Clinical Endocrinology & Metabolism. 2001;86(6):2391-2394. [pmid: 11397828].
Cohen AJ, Bartlik B. Ginkgo biloba for antidepressant-induced sexual dysfunction.[see comment]. J Sex Marital Ther. 1998;24(2):139-143. [pmid: 9611693].
Cohen JL, Keoleian CM, Krull EA. Penile paraffinoma: Self-injection with mineral oil. J Am Acad Dermatol. 2002;47(5 SUPPL.):S251-S253. [pmid: 12399741].
Cohen JL, Keoleian CM, Krull EA. Penile paraffinoma: Self-injection with mineral oil. J Am Acad Dermatol. 2001;45(6 SUPPL.):s222-s224. [pmid: 11712066].
Cohn PF. Dementia/Alzheimer's disease, diabetes, erectile dysfunction, and other diseases of the elderly. Cardiology Review. 2005;22(9):5-24.
Cole BE. Neuroendocrine implications of opioid therapy. Current Pain & Headache Reports. 2007;11(2):89-92. [pmid: 17367585].
Collett BS, Saliba JE. Post-tensioning and splicing of precast/prestressed bridge beams to extend spans. Proceedings of SPIE - The International Society for Optical Engineering. 2002;4696:363-375.
Colombel M, Gelet A. Principles and results of high-intensity focused ultrasound for localized prostate cancer. Prostate Cancer & Prostatic Diseases. 2004;7(4):289-294. [pmid: 15452554].
Compton Michael T, Miller Andrew H. Priapism associated with conventional and atypical antipsychotic medications: A review. [References]. Hillside J Clin Psychiatry. 2001;62(5):362-366.
Compton Michael T, Saldivia Aida, Berry Sally A. Recurrent priapism during treatment with clozapine and olanzapine. Am J Psychiatry. 2000;157(4):659.
Conaglen HM, Suttie JM, Conaglen JV. Effect of Deer Velvet on Sexual Function in Men and Their Partners: A Double-Blind, Placebo-Controlled Study. Arch Sex Behav. 2003;32(3):271-278. [pmid: 12807299].
Concannon P, Roberts P, Parks J, et al. Collection of seasonally spermatozoa-rich semen by electroejaculation of laboratory woodchucks (Marmota monax), with and without removal of bulbourethral glands. Lab Anim Sci. 1996;46(6):667-675. [pmid: 9001181].
Constantinou J, Feneley MR. PSA testing: An evolving relationship with prostate cancer screening. Prostate Cancer & Prostatic Diseases. 2006;9(1):6-13. [pmid: 16314892].
Contrafouris Y. Medicinal Chemistry - XVIIth International Symposium: Pulmonary disease: 1–5 September 2002, Barcelona, Spain. IDrugs. 2002;5(10):964-965. [pmid: 14689936].
Cooke BM, Breedlove SM, Jordan CL. Both estrogen receptors and androgen receptors contribute to testosterone-induced changes in the morphology of the medial amygdala and sexual arousal in male rats. Hormones & Behavior. 2003;43(2):336-346. [pmid: 12694644].
Cooke Bradley M, Chowanadisai Winyoo, Breedlove S, et al. Post-weaning social isolation of male rats reduces the volume of the medial amygdala and leads to deficits in adult sexual behavior. Behav Brain Res. 2000;117(12):107-113. [pmid: 11099763].
Cookson MS, Phillips DL, Huff ME, et al. Analysis of microsurgical penile revascularization results by etiology of impotence. Br J Urol. 1993;149(5:Pt 2):t-12.
Cooper AJ, Cernovovsky Z. The effects of cyproterone acetate on sleeping and waking penile erections in pedophiles: Possible implications for treatment. Can J Psychiatry. 1992;37(1):33-39. [pmid: 1532338].
Cooper AJ, Sandhu S, Losztyn S, et al. A double-blind placebo controlled trial of medroxyprogesterone acetate and cyproterone acetate with seven pedophiles. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 1992;37(10):687-693. [pmid: 1473073].
Cooper Alan J, Cernovsky Zack Z. Comparison of cyproterone acetate (CPA) and leuprolide acetate (LHRH agonist) in a chronic pedophile: A clinical case study. Biol Psychiatry. 1994;36(4):269-271. [pmid: 7986892].
Coopersmith Seymour E. The search for the authentic self. Psychoanal Rev. 1997;84(3):397-416. [pmid: 9279933].
Corbin JD, Francis SH, Webb DJ. Phosphodiesterase type 5 as a pharmacologic target in erectile dysfunction. Urology. 2002;60(2 SUPPL. 2):4-11. [pmid: 12414329].
Cormio L, Bettocchi C, Ricapito V, et al. Resistance index as a prognostic factor for prolonged erection after penile dynamic colour Doppler ultrasonography. Eur Urol. 1998;33(1):94-97. [pmid: 9471048].
Cormio L, Nisen H, Selvaggi FP, et al. A positive pharmacological erection test does not rule out arteriogenic erectile dysfunction.[see comment]. Br J Urol. 1996;156(5):1628-1630.
Corona G, Petrone L, Mannucci E, et al. Psycho-biological correlates of rapid ejaculation in patients attending an andrologic unit for sexual dysfunctions. Eur Urol. 2004;46(5):615-622. [pmid: 15474272].
Corona G, Petrone L, Mannucci E, et al. The impotent couple: low desire. [Review] [46 refs]. Int J Androl. 2005;28(Suppl 2):46-52. [pmid: 16236064].
Cosgrove DJ, Gordon Z, Bernie JE, et al. Sexual dysfunction in combat veterans with post-traumatic stress disorder. Urology. 2002;60(5):881-884. [pmid: 12429320].
Costa P, Sarrazin B, Bressolle F, et al. Is the volume injected a parameter likely to influence the erectile response observed after intracavernous administration of an alpha-blocking agent?. Eur Urol. 1993;24(1):43-47. [pmid: 8365438].
Costabile RA. Transurethral therapy for the treatment of erectile dysfunction: Infant or dinosaur?. Mol Urol. 1999;3(2):135-139. [pmid: 10851315].
Costabile RA. Topical alprostadil for the treatment of female sexual arousal disorder. Women's Health. 2006;2(3):331-340.
Costabile RA, Steers WD. How can we best characterize the relationship between erectile dysfunction and benign prostatic hyperplasia?. Br J Sex Med. 2006;3(4):676-681.
Couper J, Bloch S, Love A, et al. Psychosocial adjustment of female partners of men with prostate cancer: a review of the literature. [Review] [47 refs]. Psychooncology. 2006;15(11):937-953. [pmid: 16521081].
Cournoyer Barry. Male erectile difficulty: Crisis intervention and short-term treatment. Roberts, Albert R (Ed) 1990;(1990):treatment-278.
Courtois FJ, Charvier KF, Leriche A, et al. Clinical approach to erectile dysfunction in spinal cord injured men. A review of clinical and experimental data. [Review] [60 refs]. Paraplegia. 1995;33(11):628-635. [pmid: 8584296].
Courtois FJ, Gonnaud PM, Charvier KF, et al. Sympathetic skin responses and psychogenic erections in spinal cord injured men. Proc Annu Clin Spinal Cord Inj Conf. 1998;36(2):125-131.
Courtois Frederique J. Residual erectile capacity of paraplegic rats. Dissertation Abstracts International 1991;51(9-B):Mar
Courtois Frederique J, MacDougall Jamie C, Sachs Benjamin D. Erectile mechanism in paraplegia. Physiol Behav. 1993;53(4):721-726. [pmid: 8511177].
Courtois Frederique, Mathieu Catherine, Charvier Kathleen F, et al. Sexual rehabilitation for men with spinal cord injury: Preliminary report on a behavioral strategy. [References]. Sex Disabil. 2001;19(2):149-157.
Cox R. Medicinal Chemistry - 28th National Symposium: 8–12 June 2002, San Diego, CA, USA. IDrugs. 2002;5(7):626-632. [pmid: 14686338].
Cranston-Cuebas MA, Barlow DH, Mitchell W, et al. Differential effects of a misattribution manipulation on sexually functional and dysfunctional men. J Abnorm Psychol. 1993;102(4):525-533. [pmid: 8282920].
Cranston-Cuebas Margaret, Anne. Attentional focus and the misattribution of male sexual arousal. Dissertation Abstracts International: Section B: The Sciences and Engineering 1995;55(11-B):May
Crasilneck Harold B. Hypnotic techniques for smoking control and psychogenic impotence. Am J Clin Hypn. 1990;32(3):147-153. [pmid: 2296915].
Crespo-Facorro B, Perez-Iglesias R, Ramirez-Bonilla M, et al. A practical clinical trial comparing haloperidol, risperidone, and olanzapine for the acute treatment of first-episode nonaffective psychosis. Hillside J Clin Psychiatry. 2006;67(10):1511-1521.
Crimmel AS, Conner CS, Monga M. Withered Yang: A review of traditional Chinese medical treatment of male infertility and erectile dysfunction. J Androl. 2001;22(2):173-182. [pmid: 11229790].
Critchfield A Barry, Barry. Improving training approaches. Journal of the American Deafness & Rehabilitation Association. 1992;25(4):15-20.
Croasdell G. JP Morgan Hambrecht & Quist - 21st Annual Healthcare Conference: The future of big pharma: 6–9 January 2003, San Francisco, CA, USA. IDrugs. 2003;6(2):97-101.
Crook JM. Sparing erectile structures during radiation therapy of the prostate using MRI. Nature Clinical Practice Urology. 2005;2(4):164-165.
Crook JM, Potters L, Stock RG, et al. Critical organ dosimetry in permanent seed prostate brachytherapy: defining the organs at risk. Brachytherapy. 2005;4(3):186-194. [pmid: 16182218].
Csoka Antonei B, Shipko Stuart, et al. Letters to the Editor: Persistent Sexual Side Effects after SSRI Discontinuation. [References]. Psychother Psychosom. 2006;75(3):187-188. [pmid: 16636635].
Cui D, Hu L, Li S, et al. Restoration of erectile function by reconstructing cavernous nerves with sural nerve grafts. Zhonghua Nan Ke Xue. 2004;10(5):330-333. [pmid: 15190821].
Cunningham GR, Hirshkowitz M. Inhibition of steroid 5 alpha-reductase with finasteride: sleep-related erections, potency, and libido in healthy men. Journal of Clinical Endocrinology & Metabolism. 1995;80(6):1934-1940. [pmid: 7775644].
Cunningham GR, Hirshkowitz M, Korenman SG, et al. Testosterone replacement therapy and sleep-related erections in hypogonadal man. Journal of Clinical Endocrinology & Metabolism. 1990;70(3):792-797. [pmid: 2307732].
Curri SB. Topic drugs for treatment of dysfunctional disorders of penile spraying. FARMACI TOPICI PER LE TURBE DISFUNZIONALI DELLA IRRORAZIONE PENIENA: GLI EFFETTI DI UN DERIVATO FOSFOLIPIDICO DEL 3-O-BETA- IDROSSIETIL-RUTOSIDE SUI PARAMETRI MICROVASCULOGENETICI DEL DANNO CIRCOLATORIO. Policlinico - Sezione Medica. 1997;104(1):7-32.
Cushman WC, Cohen JD, Jones RP, et al. Comparison of the fixed combination of enalapril/diltiazem ER and their monotherapies in stage 1 to 3 essential hypertension. American journal of hypertension : journal of the American Society of Hypertension. 1998;11(1 Pt 1):23-30.
Cutler AJ. Sexual dysfunction and antipsychotic treatment. Psychoneuroendocrinology. 2003;28(SUPPL. 1):69-82. [pmid: 12504073].
d'Ancona FCH, Debruyne FMJ. Endocrine approaches in the therapy of prostate carcinoma. Hum Reprod Update. 2005;11(3):309-317. [pmid: 15790600].
D'haese S, Bottomley A. Short- and long-term HRQOL issues following brachytherapy for prostate cancer. Expert Review of Pharmacoeconomics & Outcomes Research. 2004;4(3):277-286. [pmid: 19807310].
D'haese S, Bottomley A, Efficace F. External beam radiotherapy in prostate cancer patients: Short- and long-term health-related quality of life issues. Expert Review of Pharmacoeconomics & Outcomes Research. 2003;3(4):487-495. [pmid: 19807459].
da Silva FC, Bono A, Whelan P, et al. Intermittent androgen deprivation for locally advanced prostate cancer: preliminary experience from an ongoing randomized controlled study of the South European urooncological group. Oncology. 2003;65(Suppl 1):24-28. [pmid: 12949430].
da Silva FC, Fossa SD, Aaronson NK, et al. The quality of life of patients with newly diagnosed M1 prostate cancer: experience with EORTC clinical trial 30853. Eur J Cancer. 1996;32A(1):72-77. [pmid: 8695246].
Da Silva JP, Santiago L, Goncalves JC. The corpus cavernous electromyography in the erectile dysfunction diagnosis. Acta Chir Hung. 1994;34(34):243-252. [pmid: 7618375].
Dachille G, Cardo G, Erinnio M, et al. Penile Doppler ultrasound assessment of the cavernous arteries. Arch Ital Urol Androl. 2005;77(4):189-190. [pmid: 16444929].
Dahlof B, Sever PS, Poulter NR, et al. Prevention of cardiovascular events with an antihypertensive regimen of amlodipine adding perindopril as required versus atenolol adding bendroflumethiazide as required, in the Anglo-Scandinavian Cardiac Outcomes Trial-Blood Pressure Lowering Arm (ASCOT-BPLA): A multicentre randomised controlled trial. Lancet. 2005;366(9489):895-906. [pmid: 16154016].
Dai Q, Silverstein AD, Davies MG, et al. Systemic basic fibroblast growth factor induces favorable histological changes in the corpus cavernosum of hypercholesterolemic rabbits. Br J Urol. 2003;170(2 I):664-668.
Dai Y, Chitaley K, Webb RC, et al. Topical application of a Rho-kinase inhibitor in rats causes penile erection. Int J Impot Res. 2004;16(3):294-298. [pmid: 14961052].
Daitch JA, Angermeier KW, Lakin MM, et al. Long-term mechanical reliability of AMS 700 series inflatable penile prostheses: comparison of CX/CXM and Ultrex cylinders. Br J Urol. 1997;158(4):1400-1402.
Dal Piaz V, Castellana MC, Vergelli C, et al. Synthesis and evaluation of some pyrazolo[3,4-d]pyridazinones and analogues as PDE 5 inhibitors potentially useful as peripheral vasodilator agents. Journal of Enzyme Inhibition & Medicinal Chemistry. 2002;17(4):227-233. [pmid: 12530475].
Daly KJ, Torella F, Ashleigh R, et al. Screening, diagnosis and advances in aortic aneurysm surgery. Gerontology. 2004;50(6):349-359. [pmid: 15477695].
Daniell HW. Opioid-induced androgen deficiency. Current Opinion in Endocrinology & Diabetes. 2006;13(3):262-266.
Darouiche RO, Mansouri MD, Raad II. Efficacy of antimicrobial-impregnated silicone sections from penile implants in preventing device colonization in an animal model. Urology. 2002;59(2):303-307. [pmid: 11834416].
Das CJ, Seith A, Gamanagatti S, et al. On the AJR viewbox. Ectopic pituitary adenoma with an empty sella. AJR Am J Roentgenol. 2006;186(5):1468-1469. [pmid: 16632746].
Das UN. Is erectile dysfunction a low-grade systemic inflammatory condition?. Eur Heart J. 2007;28(5):642-643. [pmid: 17298969].
DasGupta R, Fowler CJ. Sexual and urological dysfunction in multiple sclerosis: better understanding and improved therapies. [Review] [58 refs]. Curr Opin Neurol. 2002;15(3):271-278. [pmid: 12045724].
Daskalopoulou SS, Mikhailidis DP, Elisaf M. Prevention and treatment of the metabolic syndrome. Angiology. 2004;55(6):589-612. [pmid: 15547646].
David AK, Khwaja R, Hudes GR. Treatments for improving survival of patients with prostate cancer. Drugs Aging. 2003;20(9):683-699. [pmid: 12831292].
Davidson Julian M, Rosen Raymond C. Hormonal determinants of erectile function. Rosen, Raymond C (Ed); Leiblum, Sandra Risa (Ed) 1992;(1992):378
Davies Miranda. Heroic deeds, manic defense, and intrusive identification: Some reflections on psychotherapy with a sixteen-year-old boy. Sidoli, Mara (Ed); Bovensiepen, Gustav (Ed) 1995;(1995):328
Davila HH, Rajfer J, Gonzalez-Cadavid NF. Corporal veno-occlusive dysfunction in aging rats: evaluation by cavernosometry and cavernosography. Urology. 2004;64(6):1261-1266. [pmid: 15596219].
Davis SR, Guay AT, Shifren JL, et al. Endocrine aspects of female sexual dysfunction. Br J Sex Med. 2004;1(1):82-86.
Dawson Samuel O. Buying decisions for a finishing line. 1993;1–24.
De Almeida, Claro J, Passerotti CC, et al. Extracorporeal shock wave therapy as an alternative treatment for Peyronie's disease. The American Journal of Urology Review. 2005;3(8):390-393.
De Berardis G, Pellegrini F, Franciosi M, et al. Clinical and psychological predictors of incidence of self-reported erectile dysfunction in patients with type 2 diabetes. Br J Urol. 2007;177(1):252-257.
De Cuypere, T'Sjoen Griet, Guy Beerten, et al. Sexual and Physical Health After Sex Reassignment Surgery. [References]. Arch Sex Behav. 2005;34(6):679-690. [pmid: 16362252].
de la Rosette J. Optimising Assessment and Treatment Decisions for Men with BPH. European Urology Supplements. 2006;5(12):710-715.
De la Taille A, Hayek OR, et al. Effects of a phytotherapeutic agent, PC-SPES, on prostate cancer: A preliminary investigation on human cell lines and patients. BJU Int. 1999;84(7):845-850. [pmid: 10532984].
De Luis DA, Becerra A, Lahera M, et al. A randomized cross-over study comparing cabergoline and quinagolide in the treatment of hyperprolactinemic patients. J Endocrinol Invest. 2000;23(7):428-434. [pmid: 11005266].
De Meyer JM, Thibo P. The correlation among cavernous pressure, penile rigidity and resistance index. Br J Urol. 1998;160(1):63-66.
De Meyer JM, Thibo P, Oosterlinck W. The evaluation of arterial inflow by gravity cavernosometry. Br J Urol. 1997;158(2):440-443.
de Nesnera Alexander. Successful treatment with clozapine at higher doses after clozapine-induced priapism. [References]. Hillside J Clin Psychiatry. 2003;64(11):1394-1395.
De Rose AF, Carmignani G, Corbu C, et al. Observational multicentric trial performed with doxazosin: Evaluation of sexual effects on patients with diagnosed benign prostatic hyperplasia. Urol Int. 2002;68(2):95-98. [pmid: 11834898].
De Silva Padmal. Psychological treatment of sexual problems. Int Rev Psychiatry. 1994;6(23):163-173.
de Andrade E, de Mesquita AA, Claro Jde A, et al. Study of the efficacy of Korean Red Ginseng in the treatment of erectile dysfunction. Asian J Androl. 2007;9(2):241-244. [pmid: 16855773].
De Bruin D, Dormehl IC, Du Plessis DJ, et al. Prostaglandin E1 and papaverine: a comparative study on the ability to increase the penile bloodpool as measured by the 99mTc-penogram in the baboon model. Am J Physiol Imaging. 1991;6(3):129-132. [pmid: 1772694].
De Leval J, Boca P, Youssef E, et al. Intermittent versus continuous total androgen blockade in the treatment of patients with advanced hormone-naive prostate cancer: Results of a prospective randomized multicenter trial. Clinical Prostate Cancer. 2002;1(3):163-171. [pmid: 15046691].
De Meyer JM, Oosterlinck W. Pharmacodynamics of intracavernously injected drugs and cavernous wall resistance. Eur Urol. 1997;32(2):184-189. [pmid: 9286651].
De Rosa M, Colao A, Di Sarno A, et al. Cabergoline treatment rapidly improves gonadal function in hyperprolactinemic males: a comparison with bromocriptine. Eur J Endocrinol. 1998;138(3):286-293. [pmid: 9539303].
Dean J, de Boer BJ, Graziottin A, et al. Partner Satisfaction and Successful Treatment Outcomes for Men with Erectile Dysfunction (ED). European Urology Supplements. 2006;5(13):779-785.
Dean J, de Boer BJ, Graziottin A, et al. Psychological, Social, and Behavioural Benefits for Men Following Effective Erectile Dysfunction (ED) Treatment: Men Who Enjoy Better Sex Experience Improved Psychological Well-Being. European Urology Supplements. 2006;5(13):773-778.
Dean J, de Boer BJ, Graziottin A, et al. The Role of Erection Hardness in Determining Erectile Dysfunction (ED) Treatment Outcome. European Urology Supplements. 2006;5(13):767-772.
Dean J, de Boer BJ, Graziottin A, et al. Effective Erectile Dysfunction (ED) Treatment Enables Men to Enjoy Better Sex: The Importance of Erection Hardness, Psychological Well-Being, and Partner Satisfaction. European Urology Supplements. 2006;5(13):761-766.
Debruyne F, Barkin J, van Erps P, et al. Efficacy and safety of long-term treatment with the dual 5 alpha-reductase inhibitor dutasteride in men with symptomatic benign prostatic hyperplasia. Eur Urol. 2004;46(4):488-494. [pmid: 15363566].
DeBusk RF. Erectile dysfunction therapy in special populations and applications: Coronary artery disease. Am J Cardiol. 2005;96(12 SUPPL. 2):62M-66M.
Deedwania P, Volkova N. Dyslipidemia and lipid-lowering therapy in the elderly. Expert Review of Cardiovascular Therapy. 2005;3(3):453-463. [pmid: 15889973].
Deedwania PC, Volkova N. Current treatment options for the metabolic syndrome. Curr Treat Options Cardiovasc Med. 2005;7(1):61-74. [pmid: 15913505].
Deforge D, Blackmer J, Garritty C, et al. Male erectile dysfunction following spinal cord injury: a systematic review. [Review] [60 refs]. Proc Annu Clin Spinal Cord Inj Conf. 2006;44(8):465-473.
Deisenhammer Eberhard A, Trawoger Rudolf. Penile anesthesia associated with sertraline use. [References]. Hillside J Clin Psychiatry. 1999;60(12):869-870.
Del Monte P, Foppiani L, Ruelle A, et al. Clinically non-functioning pituitary macroadenomas in the elderly. Aging-Clinical & Experimental Research. 2007;19(1):34-40. [pmid: 17332719].
Delate T, Simmons VA, Motheral BR. Patterns of use of sildenafil among commercially insured adults in the United States: 1998-2002. Int J Impot Res. 2004;16(4):313-318. [pmid: 14973524].
Deleu D, Hanssens Y, Northway MG. Subcutaneous apomorphine: An evidence-based review of its use in Parkinson's disease. Drugs Aging. 2004;21(11):687-709. [pmid: 15323576].
Deliveliotis C, Delis A, Papatsoris A, et al. Local steroid application during nerve-sparing radical retropubic prostatectomy. BJU Int. 2005;96(4):533-535. [pmid: 16104905].
Delk IIJ, Knoll LD, McMurray J, et al. Early experience with the American Medical Systems new Tactile Pump: Results of a multicenter study. Br J Sex Med. 2005;2(2):266-271.
Della Chiesa A, Pfiffner D, Meier B, et al. Sexual activity in hypertensive men. J Hum Hypertens. 2003;17(8):515-521. [pmid: 12874608].
Della M M, Renzi G, Renzi C et al. Low molecular weight heparins in chronic venous insufficiency: Controlled trial of parnaparin efficacy and tolerability. Br J Clin Res 1993;429–36.
Demakis George J. Sex and the Brain. [References]. McAnulty, Richard D (Ed); Burnette, M 2006;Michele(Ed):2–36.
Denil J, Ohl DA, Smythe C. Vacuum erection device in spinal cord injured men: Patient and partner satisfaction. Archives of Physical Medicine & Rehabilitation. 1996;77(8):750-753. [pmid: 8702367].
Denys P, Mane M, Azouvi P, et al. Side effects of chronic intrathecal baclofen on erection and ejaculation in patients with spinal cord lesions. Archives of Physical Medicine & Rehabilitation. 1998;79(5):494-496. [pmid: 9596387].
DePalma RG, Olding M, Yu GW, et al. Vascular interventions for impotence: Lessons learned. Eur J Vasc Surg. 1995;21(4):576-585.
DePalma RG, Schwab FJ, Emsellem HA, et al. Noninvasive assessment of impotence. Surg Clin North Am. 1990;70(1):119-132. [pmid: 2406961].
Derby CA, Mohr BA, Goldstein I, et al. Modifiable risk factors and erectile dysfunction: can lifestyle changes modify risk?. Urology. 2000;56(2):302-306. [pmid: 10925098].
Derouet H, Jost WH, Osterhage J, et al. Penile sympathic skin response in erectile dysfunction. Eur Urol. 1995;28(4):314-319. [pmid: 8575499].
Derry FA, Dinsmore WW, Fraser M, et al. Efficacy and safety of oral sildenafil (Viagra) in men with erectile dysfunction caused by spinal cord injury. Neurology. 1998;51(6):1629-1633. [pmid: 9855514].
Desai Vinod, Srinivasan Nagan. Development, analysis and design of a 292 ft tall self-erecting flare tower for offshore application. Proceedings of the International Conference on Offshore Mechanics and Arctic Engineering - OMAE. 1995;1(Part B):77-88.
Desgrandchamps F. Who will benefit from combination therapy? The role of 5 alpha reductase inhibitors and alpha blockade: A reflection from MTOPS. Curr Opin Urol. 2004;14(1):17-20. [pmid: 15091044].
Devan BD, Duffy KB, Bowker JL, et al. Phosphodiesterase type 5 (PDE5) inhibition and cognitive enhancement. Drugs of the Future. 2005;30(7):725-736.
DeVries CR, Anderson RU. Endoscopic urethroplasty: An improved technique. Br J Urol. 1990;143(6):1225-1226.
DeWire DM, Todd E, Meyers P. Patient satisfaction with current impotence therapy. Wis Med J. 1995;94(10):542-544. [pmid: 8560907].
Dey J, Shepherd MD. Evaluation and treatment of erectile dysfunction in men with diabetes mellitus. Mayo Clin Proc. 2002;77(3):276-282. [pmid: 11888032].
Di Matteo Vincenzo, Giovanni Guiseppe, et al. SB 242084: A selective 5-HT-sub(2C) receptor antagonist. CNS Drug Rev. 2000;6(3):195-205.
Di Stasi SM, Giannantoni A, Stephen RL, et al. A prospective, randomized study using transdermal electromotive administration of verapamil and dexamethasone for Peyronie's disease.[see comment]. Br J Urol. 2004;171(4):1605-1608.
Di Lorenzo G, Autorino R, Perdona S, et al. Management of gynaecomastia in patients with prostate cancer: A systematic review. Lancet Oncol. 2005;6(12):972-979. [pmid: 16321765].
Di Rocco A, Tagliati M, Danisi F, et al. A pilot study of L-methionine for the treatment of AIDS-associated myelopathy. Neurology. 1998;51(1):266-268. [pmid: 9674817].
Di Silverio F, Serio M, D'Eramo G, et al. Zoladex vs. Zoladex plus cyproterone acetate in the treatment of advanced prostatic cancer: a multicenter Italian study. Eur Urol. 1990;18(Suppl):61. [pmid: 2401309].
DiBenedetti DB, Gondek K, Sagnier PP, et al. The treatment satisfaction scale: a multidimensional instrument for the assessment of treatment satisfaction for erectile dysfunction patients and their partners. Eur Urol. 2005;48(3):503-511. [pmid: 15964130].
DiBiase SJ, Wallner K, Tralins K, et al. Brachytherapy radiation doses to the neurovascular bundles. Int J Radiat Oncol Biol Phys. 2000;46(5):1301-1307. [pmid: 10725644].
Dickson Ruth A, Edwards Alun. Clozapine and fertility. Am J Psychiatry. 1997;154(4):582-583.
Dingli D, Tefferi A. A critical review of anagrelide therapy in essential thrombocythemia and related disorders. Leuk Lymphoma. 2005;46(5):641-650. [pmid: 16019501].
Dingli D, Tefferi A. Anagrelide: An update on its mechanisms of action and therapeutic potential. Expert Rev Anticancer Ther. 2004;4(4):533-541. [pmid: 15270658].
Dinsmore WW. Clinical aspects of erectile dysfunction. Int J STD AIDS. 1996;7(Suppl 3):2-4. [pmid: 8876371].
Dinsmore WW, Hackett G, Goldmeier D, et al. Topical eutectic mixture for premature ejaculation (TEMPE): A novel aerosol-delivery form of lidocaine-prilocaine for treating premature ejaculation. BJU Int. 2007;99(2):369-375. [pmid: 17129234].
Dinsmore WW, Ralph DJ, Kell P, et al. Evaluation of the Sexual Assessment Monitor, a diagnostic device used to electronically quantify ejaculatory latency time: findings from three studies. BJU Int. 2006;98(3):613-618. [pmid: 16925762].
Diomedi M, Sallustio F, Rizzato B, et al. Sildenafil increases cerebrovascular reactivity: A transcranial Doppler study. Neurology. 2005;65(6):919-921. [pmid: 16051646].
Dishy V, Sofowora G, Harris PA, et al. The effect of sildenafil on nitric oxide-mediated vasodilation in healthy men. Clinical Pharmacology & Therapeutics. 2001;70(3):270-279. [pmid: 11557915].
Dittrich A, Vandendris M. Preoperative assessment of penile curvature by artificial erection. Br J Urol. 1990;143(6):1238.
Dixon CM. Right-angle free beam lasers for the treatment of benign prostatic hyperplasia. Semin Urol. 1994;12(3):165-169. [pmid: 7527922].
Djamilian M, Stief CG, Hartmann U, et al. Predictive value of real-time RigiScan monitoring for the etiology of organogenic impotence. Br J Urol. 1993;149(5 Pt 2):1269-1271.
Djavan B, Seitz C, Marberger M. Transurethral microwave thermotherapy. Atlas of the Urologic Clinics of North America. 2002;10(1):63-73.
Doggrell S. Do vardenafil and tadalafil have advantages over sildenafil in the treatment of erectile dysfunction?. Int J Impot Res. 2007;19(3):281-295. [pmid: 17183346].
Doggrell SA. After ALLHAT: doxazosin for the treatment of benign prostatic hyperplasia. [Review] [38 refs]. Expert Opin Pharmacother. 2004;5(9):1957-1964. [pmid: 15330733].
Doggrell SA. Combination of finasteride and doxazosin for the treatment of benign prostatic hyperplasia. Expert Opin Pharmacother. 2004;5(5):1209-1211. [pmid: 15155119].
Doggrell SA. Is amlodipine the best initial monotherapy for hypertension?. Expert Opin Pharmacother. 2006;7(6):829-832. [pmid: 16556097].
Dogra PN, Aron M, Rajeev TP. Core through urethrotomy with the neodymium:YAG laser for posttraumatic obliterative strictures of the bulbomembranous urethra. Br J Urol. 1999;161(1):81-84.
Dogra PN, Rajeev TP, Aron M. Medicolegal aspects in the management of erectile dysfunction. Journal of Forensic Medicine & Toxicology. 1997;14(2):52-56.
Doherty PC, Bivalacqua TJ, Champion HC, et al. Direct effects of selective type 5 phosphodiesterase inhibitors alone or with other vasodilators on the erectile response in cats. Br J Urol. 2001;165(3):1004-1009.
Donatucci CF, Greenfield JM. Recovery of sexual function after prostate cancer treatment. [Review] [30 refs]. Curr Opin Urol. 2006;16(6):444-448. [pmid: 17053525].
Donatucci Craig F, Lue Tom F. Pathophysiology of sexual dysfunction in males with physical disabilities. Haseltine, Florence P (Ed); Cole, Sandra S (Ed); Gray, David B (Ed) 1993;(1993):368
Donnelly BJ, Saliken JC, Ernst DS, et al. Role of transrectal ultrasound guided salvage cryosurgery for recurrent prostate carcinoma after radiotherapy. Prostate Cancer & Prostatic Diseases. 2005;8(3):235-242. [pmid: 15983627].
Donovan Denis M. Therapeutic play. Journal of the American Academy of Child & Adolescent Psychiatry. 1997;36(1):3-5. [pmid: 9000770].
Dorey G. Pelvic floor exercises as a treatment for men with erectile dysfunction. [Review] [4 refs]. Nurs Times. 2004;100(12):65-67. [pmid: 15067916].
Dorey G. Is smoking a cause of erectile dysfunction? A literature review. [Review] [53 refs]. Br J Nurs. 2001;10(7):455-465. [pmid: 12070390].
Dorey G. Conservative treatment of erectile dysfunction. 3: Literature review. [Review] [25 refs]. Br J Nurs. 2000;9(13):859-863. [pmid: 11261059].
Dorey G. Conservative treatment of erectile dysfunction. 2: Clinical trials. [Review] [16 refs]. Br J Nurs. 2000;9(12):755-762. [pmid: 11235296].
Dorey G. Conservative treatment of erectile dysfunction. 1: Anatomy/physiology. [Review] [35 refs]. Br J Nurs. 2000;9(11):691-694. [pmid: 11235260].
Dorey G. Restoring pelvic floor function in men: review of RCTs. [Review][17 refs]. Br J Nurs 2005; 14(19): 1014–1018, 1020–1.
Dorey G, Feneley RC, Speakman MJ, et al. Pelvic floor muscle exercises and manometric biofeedback for erectile dysfunction and postmicturition dribble: three case studies. Journal of Wound, Ostomy, & Continence Nursing. 2003;30(1):44-51.
Dorey G, Speakman MJ, Feneley RC, et al. Pelvic floor exercises for erectile dysfunction. BJU Int. 2005;96(4):595-597. [pmid: 16104916].
Dorey G, Speakman M, Feneley R, et al. Pelvic floor exercises for treating post-micturition dribble in men with erectile dysfunction: a randomized controlled trial. Urol Nurs. 2004;24(6):490-497. [pmid: 15658735].
Dorey G, Speakman M, Feneley R, et al. Randomised controlled trial of pelvic floor muscle exercises and manometric biofeedback for erectile dysfunction. Br J Gen Pract. 2004;54(508):819-825. [pmid: 15527607].
Dorflinger T, Jensen FS, Krarup T, et al. Transurethral prostatectomy compared with incision of the prostate in the treatment of prostatism caused by small benign prostate glands. Scandinavian Journal of Urology & Nephrology. 1992;26(4):333-338. [pmid: 1284003].
Dorr RT, Lines R, Levine N, et al. Evaluation of melanotan-II, a superpotent cyclic melanotropic peptide in a pilot phase-I clinical study. Life Sci. 1996;58(20):1777-1784. [pmid: 8637402].
Dorrance AM, Lewis RW, Mills TM. Captopril treatment reverses erectile dysfunction in male stroke prone spontaneously hypertensive rats. Int J Impot Res. 2002;14(6):494-497. [pmid: 12494284].
Dos Reis JM, Glina S, Da Silva MF, et al. Penile prosthesis surgery with the patient under local regional anesthesia. Br J Urol. 1993;150(4):1179-1181.
Dossenbach Martin, Hodge Andrew, Anders Martin, et al. Prevalence of sexual dysfunction in patients with schizophrenia: International variation and underestimation. [References]. Int J Neuropsychopharmacol. 2005;8(2):195-201. [pmid: 15631645].
Dossey L. Listerine's Long Shadow: Disease Mongering and the Selling of Sickness. Explore-The Journal of Science & Healing. 2006;2(5):379-385.
Dossey L. Truth and Healing: A Time for Hard Questions. Explore-The Journal of Science & Healing. 2005;1(4):235-240.
Douchez J, Droz JP, Desclaux B, et al. Quality of life in long-term survivors of nonseminomatous germ cell testicular tumors. Br J Urol. 1993;149(3):498-501.
Douglass MA, Lin JC. Update on the treatment of benign prostatic hyperplasia. Hosp Formul. 2005;40(2):50-64.
Doust J, Miller E, Duchesne G, et al. A systematic review of brachytherapy. Is it an effective and safe treatment for localised prostate cancer?. [Review] [0 refs]. Aust Fam Physician. 2004;33(7):525-529. [pmid: 15301172].
Dow JA, Gluck RW, Golimbu M, et al. Multiphasic diagnostic evaluation of arteriogenic, venogenic, and sinusoidogenic impotency. Value of noninvasive tests compared with penile duplex ultrasonography. Urology. 1991;38(5):402-407. [pmid: 1949448].
Drago JR, Badalament RA, Nesbitt JA. Radical prostatectomy 1972-1987 single institutional experience: Comparison of standard radical prostatectomy and nerve-sparing technique. Urology. 1990;35(5):377-380. [pmid: 1692432].
Drake Virginia KE. Nontraditional psychiatric practice issues: My time in prison with women survivors of IPV. [References]. Issues Ment Health Nurs. 2007;28(2):231-237. [pmid: 17365172].
Dresser MJ, Desai D, Gidwani S, et al. Dapoxetine, a novel treatment for premature ejaculation, does not have pharmacokinetic interactions with phosphodiesterase-5 inhibitors. Int J Impot Res. 2006;18(1):104-110. [pmid: 16307008].
Droste DW, Ritter MA, Dittrich R, et al. Arterial hypertension and ischaemic stroke. Acta Neurol Scand. 2003;107(4):241-251. [pmid: 12675696].
Droupy S, Hessel A, Benoit G, et al. Assessment of the functional role of accessory pudendal arteries in erection by transrectal color Doppler ultrasound. Br J Urol. 1999;162(6):1987-1991.
Droupy S, Ponsot Y, Giuliano F. How, why and when should urologists evaluate male sexual function?. Nature Clinical Practice Urology. 2006;3(2):84-94. [pmid: 16470207].
du Plessis SS, de Jongh PS, Franken DR. Effect of acute in vivo sildenafil citrate and in vitro 8-bromo-cGMP treatments on semen parameters and sperm function. Fertility & Sterility. 2004;81(4):1026-1033. [pmid: 15066459].
Dubbelman YD, Dohle GR, Schroder FH. Sexual Function Before and After Radical Retropubic Prostatectomy: A Systematic Review of Prognostic Indicators for a Successful Outcome. Eur Urol. 2006;50(4):711-720. [pmid: 16846679].
Dubocq F, Tefilli MV, Gheiler EL, et al. Long-term mechanical reliability of multicomponent inflatable penile prosthesis: Comparison of device survival. Urology. 1998;52(2):277-281. [pmid: 9697794].
Duby JJ, Campbell RK, Setter SM, et al. Diabetic neuropathy: An intensive review. Am J Health Syst Pharm. 2004;61(2):160-176. [pmid: 14750401].
Ducharme Stanley. From the Editor. Sex Disabil. 2006;24(3):127-129.
Duckworth K. Running an erectile dysfunction clinic.[see comment]. Pap Natl Conf Prof Nurses Physicians. 1997;12(11):775-778.
Dugoua JJ, Mills E, Perri D, et al. Safety and efficacy of ginkgo (ginkgo biloba) during pregnancy and lactation. Can J Clin Pharmacol. 2006;13(3):e277-e284. [pmid: 17085776].
Duncan GG, Philips N, Pickles T. Report on the quality of life analysis from the phase III trial of pion versus photon radiotherapy in locally advanced prostate cancer. Eur J Cancer. 2000;36(6):759-765. [pmid: 10762749].
Dundar M, Kocak I, Dundar SO, et al. Evaluation of side effects of sildenafil in group of young healthy volunteers. International Urology & Nephrology. 2001;32(4):705-708. [pmid: 11989569].
Dunkel L. Use of aromatase inhibitors to increase final height. Molecular & Cellular Endocrinology 2006;254-255207-216.
Dunlop John, Marquis Karen L, Lim HK, et al. Pharmacological profile of the 5-HT-sub(2c) receptor agonist WAY-163909; therapeutic potential in multiple indications. [References]. CNS Drug Rev. 2006;12(34):167-177. [pmid: 17227285].
Dunn KM, Croft PR, Hackett GI. Association of sexual problems with social, psychological, and physical problems in men and women: a cross sectional population survey. Journal of Epidemiology & Community Health. 1999;53(3):144-148. [pmid: 10396490].
Dunn KM, Croft PR, Hackett GI. Sexual problems: a study of the prevalence and need for health care in the general population. Fam Pract. 1998;15(6):519-524. [pmid: 10078790].
Dursteler-MacFarland KM, Stohler R, Moldovanyi A, et al. Complaints of heroin-maintained patients: A survey of symptoms ascribed to diacetylmorphine. Drug & Alcohol Dependence. 2006;81(3):231-239. [pmid: 16135401].
Duschek EJJ, Gooren LJ, Netelenbos C. Effects of raloxifene on gonadotrophins, sex hormones, bone turnover and lipids in healthy elderly men. Eur J Endocrinol. 2004;150(4):539-546. [pmid: 15080785].
Dusing R. Sexual dysfunction in male patients with hypertension: influence of antihypertensive drugs. [Review] [75 refs]. Drugs. 2005;65(6):773-786. [pmid: 15819590].
Dutkiewicz S. Long-term treatment with doxazosin in men with benign prostatic hyperplasia: 10-year follow-up. International Urology & Nephrology. 2004;36(2):169-173. [pmid: 15368687].
Dutta TC, Eid JF. Vacuum constriction devices for erectile dysfunction: a long-term, prospective study of patients with mild, moderate, and severe dysfunction. Urology. 1999;54(5):891-893. [pmid: 10565753].
Dvorkin L, Song KY, Miranda Massari. Herbs for benign prostatic hyperplasia. Ann Pharmacother. 2002;36(9):1443-1452. [pmid: 12196065].
Eardley I. Optimisation of PDE5 Inhibitor Therapy in Men with Erectile Dysfunction: Converting ‘Non-Responders’ into ‘Responders’. Eur Urol. 2006;50(1):31-33. [pmid: 16517052].
Eardley I. Can an erectogenic pharmacotherapy regimen after radical prostatectomy improve postoperative erectile function?. Nature Clinical Practice Urology. 2006;3(2):72-73.
Earle CM, Seah M, Coulden SE, et al. The use of the vacuum erection device in the management of erectile impotence. Int J Impot Res. 1996;8(4):237-240. [pmid: 8981174].
East Marion L, Hofer Heribert, Wickler Wolfgang. The erect ‘penis’ is a flag of submission in a female-dominated society: Greetings in Serengeti spotted hyenas. Behav Ecol Sociobiol. 1993;33(6):355-370.
Eberhard J, Lindstrom E, Holstad M, et al. Prolactin level during 5 years of risperidone treatment in patients with psychotic disorders. Acta Psychiatr Scand. 2007;115(4):268-276. [pmid: 17355517].
Eden CG, Cahill D, Vass JA, et al. Laparoscopic radical prostatectomy: The initial UK series. BJU Int. 2002;90(9):876-882. [pmid: 12460349].
Edmondson JD, Hatcher PA, McGrath RS, et al. Noninvasive evaluation of vasculogenic impotence. Journal of Vascular Technology. 1994;18(3):125-127.
Eglau Uwe. Brief therapy for sexual dysfunction. International Forum for Logotherapy. 1992;15(2):108-110.
Ehrensaft MK, Condra M, Morales A, et al. Communication patterns in patients with erectile dysfunction and their partners. Int J Impot Res. 1994;6(1):25-32. [pmid: 8019614].
Ei-Bahnasawy MS, Gomha MA. Penile fractures: The successful outcome of immediate surgical intervention. Int J Impot Res. 2000;12(5):273-277. [pmid: 11424965].
Eilenberg KL, Hoover AM, Rutherford ML, et al. From informed consent through database lock: An interactive clinical trial conducted using the internet. Drug Inf J. 2004;38(3):239-251.
Ekman P. A risk-benefit assessment of treatment with finasteride in benign prostatic hyperplasia. [Review] [32 refs]. Drug Saf. 1998;18(3):161-170. [pmid: 9530536].
el-Abd SA. Endoscopic treatment of posttraumatic urethral obliteration: experience in 396 patients. Br J Urol. 1995;153(1):67-71.
El-Bahrawy M, El-Baz MA, Emam A, et al. Noninvasive vacuum constriction device in the management of erectile dysfunction. International Urology & Nephrology. 1995;27(3):331-333. [pmid: 7591599].
El-Gabry EA, Strup SE, Gomella LG. Deciding on radical prostatectomy: The physician's perspective. Semin Urol Oncol. 2000;18(3):205-213. [pmid: 10975493].
El-Hakim A, Leung RA, Tewari A. Robotic prostatectomy: A pooled analysis of published literature. Expert Rev Anticancer Ther. 2006;6(1):11-20. [pmid: 16375639].
El-Latif MA, Makhlouf AA, Moustafa YM, et al. Diagnostic value of nitric oxide, lipoprotein(a), and malondialdehyde levels in the peripheral venous and cavernous blood of diabetics with erectile dysfunction. Int J Impot Res. 2006;18(6):544-549. [pmid: 16625232].
El-Rayes BF, Hussain MH. Hormonal therapy for prostate cancer: Past, present and future. Expert Rev Anticancer Ther. 2002;2(1):37-47. [pmid: 12113064].
El-Sakka AI. Prevalence of Peyronie's disease among patients with erectile dysfunction. Eur Urol. 2006;49(3):564-569. [pmid: 16386353].
El-Sakka AI. Lower urinary tract symptoms in patients with erectile dysfunction: is there a vascular association?. Eur Urol. 2005;48(2):319-325. [pmid: 15964128].
El-Sakka AI. Cardiovascular system as a ‘core’ of sexual life. Expert Opin Pharmacother. 2005;6(13):2223-2230. [pmid: 16218883].
El-Sakka AI, Morsy AM. Screening for ischemic heart disease in patients with erectile dysfunction: role of penile Doppler ultrasonography. Urology. 2004;64(2):346-350. [pmid: 15302492].
El-Sakka AI, Lin CS, Chui RM, et al. Effects of diabetes on nitric oxide synthase and growth factor genes and protein expression in an animal model. Int J Impot Res. 1999;11(3):123-132. [pmid: 10404280].
El-Sakka AI, Rashwan HM, Lue TF. Venous patch graft for Peyronie's disease. Part II: outcome analysis.[erratum appears in J Urol 1999 Sep;162(3 Pt 1):809]. Br J Urol. 1998;160(6:Pt 1):t-3.
El-Senosy Mohamed, Yousry Rabie, Mohamed Osman, et al. Changes in sexual function in epileptics. Arab Journal of Psychiatry. 1994;5(2):92-101.
El-Thaher TS, Matalka KZ, Taha HA, et al. Ferula harmonis ‘zallouh’ and enhancing erectile function in rats: Efficacy and toxicity study. Int J Impot Res. 2001;13(4):247-251. [pmid: 11494083].
Elabbady A, Hassouna MM, Elhilali M. Apomorphine versus mating behavior in testing erectile capabilities of diabetic rats. Urology. 1995;45(4):715-719. [pmid: 7716860].
Elhanbly S, bdel-Gaber S, Fathy H, et al. Erectile dysfunction in smokers: a penile dynamic and vascular study. J Androl. 2004;25(6):991-995. [pmid: 15477374].
Elhilali MM. Alfuzosin: An a1-receptor blocker for the treatment of lower urinary tract symptoms associated with benign prostatic hyperplasia. Expert Opin Pharmacother. 2006;7(5):583-596. [pmid: 16553574].
Elhilali M, Emberton M, Matzkin H, et al. Long-term efficacy and safety of alfuzosin 10 mg once daily: A 2-year experience in ‘real-life’ practice. BJU Int. 2006;97(3):513-519. [pmid: 16469018].
Eliasson T, Abramsson L, Damber JE. Importance of thermal dose and antenna location in transurethral microwave thermotherapy for benign prostatic hyperplasia. J Endourol. 1998;12(6):581-589. [pmid: 9895266].
Elist J. Effects of pollen extract preparation Prostat/Poltit on lower urinary tract symptoms in patients with chronic nonbacterial prostatitis/chronic pelvic pain syndrome: A randomized, double-blind, placebo-controlled study. Urology. 2006;67(1):60-63. [pmid: 16413333].
Elliott DS, Barrett DM. Long-term followup and evaluation of primary realignment of posterior urethral disruptions.[see comment]. Br J Urol. 1997;157(3):814-816.
Ellison Carol, Rinkleib. Intimacy-based sex therapy: Sexual choreography. [References]. Kleinplatz, Peggy J (Ed) 2001;(2001):375-Routledge.
Ellison KE, Gandhi G. Optimising the use of beta-adrenoceptor antagonists in coronary artery disease. Drugs. 2005;65(6):787-797. [pmid: 15819591].
Elves A W, Ahmed M, Abrams P. Computer-assisted learning; experience at the Bristol Urological Institute in the teaching of urology. Br J Urol 1997;.80 Suppl 3, pp.59–62, 1997 Nov.
Emberton M, Neal DE, Black N, et al. The effect of prostatectomy on symptom severity and quality of life. Br J Urol. 1996;77(2):233-247. [pmid: 8800892].
Eng TY, Thomas CR, Herman TS. Progress in the treatment of localized prostate cancer with external beam irradiation. Expert Rev Anticancer Ther. 2006;6(1):93-108.
Englert H, Schaefer G, Roll S, et al. Prevalence of erectile dysfunction among middle-aged men in a metropolitan area in Germany. Int J Impot Res. 2007;19(2):183-188. [pmid: 16885992].
Enzlin P, Mak R, Kittel F, et al. Sexual functioning in a population-based study of men aged 40–69 years: the good news. Int J Impot Res. 2004;16(6):512-520. [pmid: 15085171].
Erdogru T, Kadioglu A, Cayan S, et al. Does the positive intracavernous papaverine test always indicate a normal penile vascular system?. Eur Urol. 1997;31(3):323-328. [pmid: 9129924].
Erdogru T, Savas M, Yilmaz N, et al. Evaluation of penile hemodynamic status and adjustment of treatment alternatives in Peyronie's disease. Asian J Androl. 2002;4(3):187-190. [pmid: 12364974].
Erdogru T, Usta MF, Ates M, et al. Development of Peyronie's disease during long-term colchicine treatment. International Urology & Nephrology. 2003;35(2):207-208. [pmid: 15072497].
Eri LM, Tveter KJ. Safety, side effects and patient acceptance of the antiandrogen Casodex in the treatment of benign prostatic hyperplasia. Eur Urol. 1994;26(3):219-226. [pmid: 7528662].
Eri LM, Tveter KJ. Safety, side effects and patient acceptance of the luteinizing hormone releasing hormone agonist leuprolide in treatment of benign prostatic hyperplasia. Br J Urol. 1994;152(2:Pt 1):t-52.
Erkan E, Muslumanoglu AY, Oktar T, et al. Polymorphism of endothelial nitric oxide synthase gene in patients with erectile dysfunction. Br J Sex Med. 2006;3(1):69-75.
Erlichman M, Handelsman H, Hotta S S. Cryosurgery for recurrent prostate cancer following radiation therapy. [Review][29 refs]. Health Technology Assessment (Rockville, Md) 1999;(13):i-v.
Ernst E, Pittler MH, Wider B, et al. Acupuncture: Its evidence-base is changing. Am J Chin Med. 2007;35(1):21-25. [pmid: 17265547].
Ersay A, Nergis Y, Tok D, et al. Intracavernosal anaesthesia: The effect of intracavernosal lidocaine injection on cavernosal tissue. Acta Anaesthesiol Ital. 1996;47(4):281-286.
Esen A, Kitapci M, Ergen A, et al. Dual radioisotopic study: a technique for the evaluation of vasculogenic impotence. Br J Urol. 1992;147(1):42-46.
Esper RJ, Nordaby RA, Vilarin~o JO, et al. Endothelial dysfunction: A comprehensive appraisal. Cardiovasc Diabetol. 2006;5:2006. Article Number.
Esposito K, Ciotola M, Giugliano F, et al. Mediterranean diet improves erectile function in subjects with the metabolic syndrome. Int J Impot Res. 2006;18(4):405-410. [pmid: 16395320].
Esposito K, Giugliano F, Di Palo C, et al. Effect of lifestyle changes on erectile dysfunction in obese men: a randomized controlled trial.[see comment]. JAMA. 2004;291(24):2978-2984. [pmid: 15213209].
Estey EH. Modulation of angiogenesis in patients with myelodysplastic syndrome. Baillieres Best Practice & Research in Clinical Haematology. 2004;17(4 SPEC.ISS.):623-639.
Ethans KD, Casey AR, Schryvers OI, et al. The effects of sildenafil on the cardiovascular response in men with spinal cord injury at or above the sixth thoracic level. J Spinal Cord Med. 2003;26(3):222-226. [pmid: 14997962].
Evans MF. Critical appraisal: Lose weight to lose erectile dysfunction. Can Fam Physician. 2005;51(JAN.):47-49. [pmid: 15732221].
Everaerd Walter. Male erectile disorder. O'Donohue, William (Ed); Geer, James H (Ed) 1993;(1993):418
Evren Cuneyt, Can Suat, Evren Bilge, et al. Lifetime posttraumatic stress disorder in Turkish alcohol-dependent inpatients: Relationship with depression, anxiety and erectile dysfunction. [References]. Psychiatry Clin Neurosci. 2006;60(1):77-84. [pmid: 16472362].
Exaire Murad E, Chavez de, los Rios, et al. Lisinopril vs methyl-dopa in essential hypertension: A comparative study. Invest Med Int. 1992;18(4):163-168.
Fabbri A, Aversa A, Isidori A. Erectile dysfunction: An overview. Hum Reprod Update. 1997;3(5):455-466. [pmid: 9528911].
Fabian Jose Luis. Psychotropic medications and priapism. Am J Psychiatry. 1993;150(2):349-350. [pmid: 8422096].
Fagan Peter. Psychogenic impotence in relatively young men. Levine, Stephen B (Ed); Risen, Candace B (Ed); Althof, Stanley E (Ed) 2003;(2003):473-Routledge.
Fagan Peter J. Treatment case: A couple with sexual dysfunction and paraphilia. [References]. Costa, Paul T Jr 1994;(Ed):Thomas-factor.
Fahn S, Chouinard S. Experience with tranylcypromine in early Parkinson's disease. J Neural Transm 1998;Supplementum.52–61.
Fahrenkrug J. Gut/brain peptides in the genital tract: VIP and PACAP. Scandinavian Journal of Clinical and Laboratory Investigation Supplement. 2001;61(234):35-39. [pmid: 11713978].
Fainstein Day P, Guitelman M, Artese R, et al. Retrospective multicentric study of pituitary incidentalomas. Pituitary. 2004;7(3):145-148. [pmid: 16328565].
Fallon B. Cadaveric dura mater graft for correction of penile curvature in Peyronie disease. Urology. 1990;35(2):127-129. [pmid: 2305535].
Fandel TM, Bella AJ, Tantiwongse K, et al. The effect of intracavernosal growth differentiation factor-5 therapy in a rat model of cavernosal nerve injury. BJU Int. 2006;98(3):632-636. [pmid: 16796696].
Fanning KD, Lloyd KB. Current pharmacological treatment options for prostate cancer. P & T. 2002;27(10):500-505.
Fardella CE, Gloger S. Neurobehavioral and psychological changes induced by hyperthyroidism: Diagnostic and therapeutic implications. Expert Review of Neurotherapeutics. 2002;2(5):709-716. [pmid: 19810987].
Faria Miguel, Magalhaes-Cardoso Teresa, Lafuente-de-Carvalho Jose-Maria, et al. Corpus Cavernosum from Men with Vasculogenic Impotence is Partially Resistant to Adenosine Relaxation due to Endothelial A-sub(2B) Receptor Dysfunction. [References]. J Pharmacol Exp Ther. 2006;319(1):405-413. [pmid: 16837560].
Fava M, Rankin M. Sexual functioning and SSRIs. [Review][31 refs]. Hillside J Clin Psychiatry 2002;63Suppl-6.
Febbraro Greg A R. Sexual Arousal Disorders. [References]. McAnulty, Richard D (Ed); Burnette, M 2006;Michele(Ed):2–151.
Fecik SE. Drug-induced sexual dysfunction. Medical Update for Psychiatrists. 1998;3(6):176-181.
Fedele D, Bortolotti A, Coscelli C, et al. Erectile dysfunction in type 1 and type 2 diabetics in Italy. On behalf of Gruppo Italiano Studio Deficit Erettile nei Diabetici. Int J Epidemiol. 2000;29(3):524-531. [pmid: 10869326].
Fedele D, Coscelli C, Cucinotta D, et al. Incidence of erectile dysfunction in Italian men with diabetes. Br J Urol. 2001;166(4):1368-1371.
Fedele D, Coscelli C, Santeusanio F, et al. Erectile dysfunction in diabetic subjects in Italy. Gruppo Italiano Studio Deficit Erettile nei Diabetici. Diabetes Care. 1998;21(11):1973-1977. [pmid: 9802753].
Feher MD. Statin prescribing rises and infarct rates plateau. Why the mismatch?. British Journal of Cardiology. 2004;11(6):421-423.
Fehr JL, Alund G, Muhlebach P, et al. Significance of cavernosography in standardized cavernosometry. Urol Int. 1992;49(1):13-18. [pmid: 1413320].
Feigenberg SJ, Lee WR, Desilvio ML, et al. Health-related quality of life in men receiving prostate brachytherapy on RTOG 98-05. Int J Radiat Oncol Biol Phys. 2005;62(4):956-964. [pmid: 15989995].
Fernandez De La Maza S, Conrad S, et al. Early clinical experience with water-jet dissection (hydro-jet) during nerve-sparing radical retropubic prostatectomy. Minimally Invasive Therapy & Allied Technologies: Mitat. 2002;11(56):257-264.
Fernandez HH, Trieschmann ME, Friedman JH. Treatment of psychosis in Parkinson's disease: Safety considerations. Drug Saf. 2003;26(9):643-659. [pmid: 12814332].
Ferrario CM, Levy P. Sexual dysfunction in patients with hypertension: implications for therapy. [Review] [49 refs]. J Clin Hypertens. 2002;4(6):424-432.
Ferraz Marcos, Rochedo Ferraz, Marcia Martins, et al. Preventing L-NAME inhibitory effects on rat sexual behavior with hydralazine, isradipine or captopril co-treatment. [References]. Pharmacology, Biochemistry and Behavior. 2003;75(2):265-272.
Ferrer E, Moral MA, Bozzo J. The role of statins in erectile dysfunction. Med Actual. 2007;43(1):55-59.
Ferri C, Giuggioli D, Cazzato M, et al. HCV-related cryoglobulinemic vasculitis: An update on its etiopathogenesis and therapeutic strategies. Clinical & Experimental Rheumatology. 2003;21(6 SUPPL. 32):S78-S84. [pmid: 14740431].
Ferrini M, Magee TR, Vernet D, et al. Aging-related expression of inducible nitric oxide synthase and markers of tissue damage in the rat penis. Biol Reprod. 2001;64(3):974-982. [pmid: 11207215].
Fietkau R, Riepl M, Kettner H, et al. Supportive treatment with megestrol acetate during radio-(chemo-) therapy. A randomized trial. Sonderb Z Strahlenther Onkol. 1996;172(3):162-168.
Filippi S, Morelli A, Sandner P, et al. Characterization and functional role of androgen-dependent PDE5 activity in the bladder. Endocrinology. 2007;148(3):1019-1029. [pmid: 17138653].
Fine Reuben. A Little New Light on an Old Profession. PsycCRITIQUES 2006;2006 American Psychological Assn.
Finelli A, Hirshberg ED, Radomski SB. The treatment choice of elderly patients with erectile dysfunction. Geriatric Nephrology & Urology. 1998;8(1):15-19. [pmid: 9650043].
Finney G, Haynes AM, Cross P, et al. Cross-sectional analysis of sexual function after prostate brachytherapy. Urology. 2005;66(2):377-381. [pmid: 16098365].
Firoozi F, Longhurst PA, White MD. In vivo and in vitro response of corpus cavernosum to phosphodiesterase-5 inhibition in the hypercholesterolaemic rabbit. BJU Int. 2005;96(1):164-168. [pmid: 15963142].
Fishbain D, Berman K, Kajdasz DK. Duloxetine for neuropathic pain based on recent clinical trials. Current Pain & Headache Reports. 2006;10(3):199-204. [pmid: 18778574].
Fishel B, Chen J, Alon M, et al. The value of testing pudendal nerve conduction in evaluating erectile dysfunction in diabetics. Int J Impot Res. 2000;12(2):103-105. [pmid: 11052636].
Fisher Jane E, Ed O'Donohue, William T. Practitioner's guide to evidence-based psychotherapy. (2006) 2006;vi, 754 pp. New York, NY, US754
Fitch WP, Easterling WJ, Talbert RL, et al. Topical verapamil HCl, topical trifluoperazine, and topical magnesium sulfate for the treatment of Peyronie's Disease - A Placebo-Controlled Pilot Study. Br J Sex Med. 2007;4(2):477-484.
Fitch William, Tecumseh Sherman. Vocal tract length perception and the evolution of language. Dissertation Abstracts International: Section B: The Sciences and Engineering 1995;55(7-B):Jan
Fitzgerald SW, Erickson SJ, Foley WD, et al. Color Doppler sonography in the evaluation of erectile dysfunction. [Review] [15 refs]. Radiographics. 1992;12(1):3-17. [pmid: 1734478].
Fitzgerald S W, Erickson S J, Foley W D et al. Color Doppler sonography in the evaluation of erectile dysfunction: patterns of temporal response to papaverine. AJR Am J Roentgenol 1991;American Journal of Roentgenology. 157(2):331–336.
Fitzpatrick JM, Artibani W. Therapeutic Strategies for Managing BPH Progression. European Urology Supplements. 2006;5(20):997-1003.
Flaherty Maria Y. Group treatment of men with erectile dysfunction: An outcome study using physiological, behavioral, and psychological assessments. Dissertation Abstracts International 1990;51(3-B):Sep
Fleshner N, Kulkarni G. Should finasteride be used to prevent prostate cancer?. [Review] [47 refs]. Curr Treat Options Oncol. 2006;7(5):346-354. [pmid: 16904051].
Fleshner NE, Trachtenberg J. Treatment of advanced prostate cancer with the combination of finasteride plus flutamide: early results. Eur Urol. 1993;24(Suppl 2):106-112. [pmid: 7505229].
Fletcher A. Quality of life in the management of hypertension. [Review] [21 refs]. Clinical & Experimental Hypertension (New York). 1999;21(56):961-972.
Fogari R, Zoppi A. Effect of antihypertensive agents on quality of life in the elderly. [Review] [125 refs]. Drugs Aging. 2004;21(6):377-393. [pmid: 15084140].
Fogari R, Zoppi A, Poletti L, et al. Sexual activity in hypertensive men treated with valsartan or carvedilol: a crossover study. Am J Hypertens. 2001;14(1):27-31. [pmid: 11206674].
Fogarty JD, Bleustein CB, Hafron JM, et al. Cutaneous temperature measurements in men with penile prostheses: a comparison study. Int J Impot Res. 2005;17(6):506-509. [pmid: 15889119].
Fonseca V, Jawa A. Endothelial and erectile dysfunction, diabetes mellitus, and the metabolic syndrome: Common pathways and treatments?. Am J Cardiol. 2005;96(12 SUPPL. 2):13M-18M. [pmid: 15979424].
Foreman Mark M, Doherty Paul C. Experimental approaches for the development of pharmacological therapies for erectile dysfunction. Riley, Alan J (Ed); Peet, Malcolm (Ed); Wilson, Catherine (Ed) 1993;(1993):235
Foresta C, Bettella A, Spolaore D, et al. Suppression of the high endogenous levels of plasma FSH in infertile men are associated with improved Sertoli cell function as reflected by elevated levels of plasma inhibin B. Hum Reprod. 2004;19(6):1431-1437. [pmid: 15117900].
Formenti SC, Lieskovsky G, Simoneau AR, et al. Impact of moderate dose of postoperative radiation on urinary continence and potency in patients with prostate cancer treated with nerve sparing prostatectomy. Br J Urol. 1996;155(2):616-619.
Formenti SC, Lieskovsky G, Skinner D, et al. Update on impact of moderate dose of adjuvant radiation on urinary continence and sexual potency in prostate cancer patients treated with nerve-sparing prostatectomy. Urology. 2000;56(3):453-458. [pmid: 10962314].
Forssmann WG, Meyer M, Forssmann K. The renal urodilatin system: Clinical implications. Cardiovasc Res. 2001;51(3):450-462. [pmid: 11476735].
Foster RS. Early-stage testis cancer. [Review] [21 refs]. Curr Treat Options Oncol. 2001;2(5):413-419. [pmid: 12057104].
Foster-Schubert KE, Cummings DE. Emerging therapeutic strategies for obesity. Endocr Rev. 2006;27(7):779-793. [pmid: 17122357].
Fourcade RO, McLeod D. Tolerability of antiandrogens in the treatment of prostate cancer. Urooncology. 2004;4(1):5-13.
Fowler FJ, Collins MM, Corkery EW, et al. The impact of androgen deprivation on quality of life after radical prostatectomy for prostate carcinoma. Cancer. 2002;95(2):287-295. [pmid: 12124828].
Fowler C, McAllister W, Plail R, et al. Randomised evaluation of alternative electrosurgical modalities to treat bladder outflow obstruction in men with benign prostatic hyperplasia. Health Technol Assess. 2005;9(4):iii-30. [pmid: 15698525].
Fraiman MC, Lepor H, McCullough AR. Changes in penile morphometrics in men with erectile dysfunction after nerve-sparing radical retropubic prostatectomy. Mol Urol. 1999;3(2):109-115. [pmid: 10851312].
Frajese G, Lazzari R, Magnani A, et al. Neurotransmitter, opiodergic system, steroid-hormone interaction and involvement in the replacement therapy of sexual disorders. J Steroid Biochem Mol Biol. 1990;37(3):411-419. [pmid: 1979499].
Francavilla S, Properzi G, Bellini C, et al. Endothelin-1 in diabetic and nondiabetic men with erectile dysfunction. Br J Urol. 1997;158(5):1770-1774.
Francis DA, Christopher AT, Beasley BD. Conservative Treatment of Peripheral Neuropathy and Neuropathic Pain. Clinics in Podiatric Medicine & Surgery. 2006;23(3):509-530. [pmid: 16958385].
Francis SH, Corbin JD. Phosphodiesterase-5 inhibition: The molecular biology of erectile function and dysfunction. Urol Clin North Am. 2005;32(4):419-429. [pmid: 16291034].
Francisca EA, d'Ancona FC, Meuleman EJ, et al. Sexual function following high energy microwave thermotherapy: results of a randomized controlled study comparing transurethral microwave thermotherapy to transurethral prostatic resection. Br J Urol. 1999;161(2):486-490.
Frankel SJ, Donovan JL, Peters TI, et al. Sexual dysfunction in men with lower urinary tract symptoms. J Clin Epidemiol. 1998;51(8):677-685. [pmid: 9743316].
Frankel S, Smith GD, Donovan J, et al. Screening for prostate cancer. Lancet. 2003;361(9363):1122-1128. [pmid: 12672328].
Franklin SS, Smith DHG, Codispoti J, et al. Combination treatment with sustained-release verapamil and indapamide in the treatment of mild-to-moderate hypertension. Am J Ther. 1996;3(3):229-236. [pmid: 11862255].
Franks S, Jacobs HS. Hyperprolactinaemia. Clinics in Endocrinology & Metabolism. 1983;12(3):641-668. [pmid: 6368054].
Fransson P, Widmark A. Self-assessed sexual function after pelvic irradiation for prostate carcinoma. Comparison with an age-matched control group. Cancer. 1996;78(5):1066-1078. [pmid: 8780545].
Frederick Mark. The hypnotherapeutic treatment of impotency: A case study. Australian Journal of Clinical Hypnotherapy and Hypnosis. 1991;12(1):61-63.
Freedland SJ, Haffner MC, Landis PK, et al. Obesity does not adversely affect health-related quality-of-life outcomes after anatomic retropubic radical prostatectomy. Urology. 2005;65(6):1131-1136. [pmid: 15913722].
Freedman AL, Costa Neto F, Mehringer CM, et al. Long-term results of penile vein ligation for impotence from venous leakage. Br J Urol. 1993;149(5 Pt 2):1301-1303.
Freundenreich Oliver. Exacerbation of idiopathic priapism with risperidone-citalopram combination. [References]. Hillside J Clin Psychiatry. 2002;63(3):249-250.
Freytag F, Schelling A, Meinicke T, et al. Comparison of 26-week efficacy and tolerability of telmisartan and atenolol, in combination with hydrochlorothiazide as required, in the treatment of mild to moderate hypertension: a randomized, multicenter study. Clin Ther. 2001;23(1):108-123. [pmid: 11219471].
Fricker J. The rise and fall of Viagra. Drug Discov Today. 2001;6(14):704-706. [pmid: 11445454].
Fritsch MJ, Bauer M, Partsch CJ, et al. Endocrine evaluation after endoscopic third ventriculostomy (ETV) in children. Childs Nerv Syst. 2007;23(6):627-631. [pmid: 17447075].
Froschermaier SE, Werner D, Leike S, et al. Enhanced external counterpulsation as a new treatment modality for patients with erectile dysfunction. Urol Int. 1998;61(3):168-171. [pmid: 9933838].
Frucht SJ. Parkinson disease: An update. Proc Aust Assoc Neurol. 2004;10(4):185-194.
Fugl-Meyer Kerstin S, Arrhult Helene, Pharmanson Helena, et al. A Swedish Telephone Help-line for Sexual Problems: A 5-year Survey. [References]. Br J Sex Med. 2004;1(3):278-283.
Fukui M, Kitagawa Y, Ose H, et al. Role of endogenous androgen against insulin resistance and athero-sclerosis in men with type 2 diabetes. Current Diabetes Reviews. 2007;3(1):25-31. [pmid: 18220653].
Funder JW. Eplerenone: Hypertension, heart failure and the importance of mineralocorticoid receptor blockade. Future Cardiology. 2006;2(5):535-541. [pmid: 19804189].
Fung MM, Bettencourt R, Barrett-Connor E. Heart disease risk factors predict erectile dysfunction 25 years later: the Rancho Bernardo Study. J Am Coll Cardiol. 2004;43(8):1405-1411. [pmid: 15093875].
Furst G, Muller-Mattheis V, Cohnen M, et al. Venous incompetence in erectile dysfunction: evaluation with color-coded duplex sonography and cavernosometry/-graphy. Eur Radiol. 1999;9(1):35-41. [pmid: 9933376].
Furtado RNV, Oliveira LM, Natour J. Polyarticular corticosteroid injection versus systemic administration in treatment of rheumatoid arthritis patients: A randomized controlled study. Br J Rheumatol. 2005;32(9):1691-1698.
Furusyo N, Hayashi J, Ueno K, et al. Human lymphoblastoid interferon treatment for patients with hepatitis C virus-related cirrhosis. Clin Ther. 1997;19(6):1352-1367. [pmid: 9444445].
Fux R, Morike K, Prohmer AMT, et al. Impact of CYP2D6 genotype on adverse effects during treatment with metoprolol: A prospective clinical study. Clinical Pharmacology & Therapeutics. 2005;78(4):378-387. [pmid: 16198657].
Gacci M, Vittori G, Giubilei G, et al. Long-term delayed extrusion of a penile prosthesis. Arch Ital Urol Androl. 2007;79(1):41-42. [pmid: 17484406].
Gaddam KK, Pratt-Ubunama MN, Calhoun DA. Aldosterone antagonists: Effective add-on therapy for the treatment of resistant hypertension. Expert Review of Cardiovascular Therapy. 2006;4(3):353-359. [pmid: 16716096].
Gades NM, Nehra A, Jacobson DJ, et al. Association between smoking and erectile dysfunction: a population-based study. Am J Epidemiol. 2005;161(4):346-351. [pmid: 15692078].
Gall H, Sparwasser CH, Stief CG, et al. Diagnosis of venous incompetence in erectile dysfunction. Comparative study of cavernosography and Doppler ultrasound. Urology. 1990;35(3):235-238. [pmid: 2180173].
Galle G, Trummer H. The etiology of erectile dysfunction and mechanisms by which drugs improve erection. Med Actual. 2003;39(3):193-201.
Gallen I, Carter C. Prospective audit of the introduction of insulin glargine (Lantus) into clinical practice in type 1 diabetes. Practical Diabetes International. 2004;21(3):110-114.
Gallo L, Perdona S, Autorino R, et al. Vesicourethral anastomosis during radical retropubic prostatectomy: does the number of sutures matter?. Urology. 2007;69(3):547-551. [pmid: 17382162].
Game X, Moscovici J, Game L, et al. Evaluation of sexual function in young men with spina bifida and myelomeningocele using the International Index of Erectile Function. Urology. 2006;67(3):566-570. [pmid: 16504267].
Ganabathi K, Dmochowski R, Zimmern PE, et al. Peyronie's disease: surgical treatment based on penile rigidity. Br J Urol. 1995;153(3:Pt 1):t-6.
Ganem JP, Lucey DT, Janosko EO, et al. Unusual complications of the vacuum erection device. [Review] [17 refs]. Urology. 1998;51(4):627-631. [pmid: 9586618].
Gannon Kenneth, Glover Lesley, Abel Paul, et al. Masculinity, infertility, stigma and media reports. [References]. Soc Sci Med. 2004;59(6):1169-1175. [pmid: 15210089].
Ganz P. Erectile dysfunction: Pathophysiologic mechanisms pointing to underlying cardiovascular disease. Am J Cardiol. 2005;96(12 SUPPL. 2):8M-12M.
Ganz PA, Greendale GA. Female sexual desire—beyond testosterone. J Natl Cancer Inst. 2007;99(9):659-661. [pmid: 17470728].
Ganzarain Ramon. Group-as-a-whole dynamics in work with traumatized patients: Technical strategies, their rationales, and limitations. [References]. Klein, Robert H (Ed); Schermer, Victor L (Ed) 2000;(2000):364
Garban H, Marquez D, Cai L, et al. Restoration of normal adult penile erectile response in aged rats by long-term treatment with androgens. Biol Reprod. 1995;53(6):1365-1372. [pmid: 8562693].
Garban H, Marquez D, Magee T, et al. Cloning of rat and human inducible penile nitric oxide synthase. Application for gene therapy of erectile dysfunction. Biol Reprod. 1997;56(4):954-963. [pmid: 9096878].
Garber B. Inflatable penile prostheses for the treatment of erectile dysfunction. Expert Review of Medical Devices. 2005;2(3):341-350. [pmid: 16288597].
Garber BB. Outpatient inflatable penile prosthesis insertion. Urology. 1997;49(4):600-603. [pmid: 9111632].
Garcia JM, Li H, Mann D, et al. Hypogonadism in male patients with cancer. Cancer. 2006;106(12):2583-2591. [pmid: 16688773].
Garcia-Campayo Javier, Sanz-Carrillo C, Lobo A. Orgasmic sexual experiences as a side effect of fluoxetine: A case report. Acta Psychiatr Scand. 1995;91(1):69-70. [pmid: 7754790].
Gardner DM, Baldessarini RJ, Waraich P. Modern antipsychotic drugs: A critical overview. CMAJ: Canadian Medical Association Journal. 2005;172(13):1703-1711. [pmid: 15967975].
Garg G, Singh D, Saraf S, et al. Management of benign prostate hyperplasia: An overview of a-adrenergic antagonist. Biol Pharm Bull. 2006;29(8):1554-1558. [pmid: 16880603].
Garippa Philip A, Sanders Nina. Resolution of erectile dysfunction and inhibited male orgasm in a single homosexual male and transfer of inhibited male orgasm cure to his partner: A case report. J Sex Marital Ther. 1997;23(2):126-130. [pmid: 9230493].
Garko SB, Ogunsina MO, Danbauchi SS. Sexual dysfunction in hypertensive patients: Implications for therapy. Annals of African Medicine. 2005;4(2):46-51.
Garnick MB, Fair WR. Prostate cancer: emerging concepts. Part II. [Review] [60 refs]. Ann Intern Med. 1996;125(3):205-212. [pmid: 8686979].
Garver DL. Evolution of antipsychotic intervention in the schizophrenic psychosis. Curr Drug Targets. 2006;7(9):1205-1215. [pmid: 17017896].
Gastal EL, Henry M, Beker AR, et al. Sexual behavior of donkey jacks: Influence of ejaculatory frequency and season. Theriogenology. 1996;46(4):593-603. [pmid: 16727925].
Gasteiger R. Safe operation of chemical plants methodology and practice of risk prevention. Journal of Occupational Accidents. 1990;13(12):145-156.
Gaston KE, Ornstein DK. Pharmacotherapy for biochemical recurrences after therapy for localised prostate cancer. [Review] [117 refs]. Expert Opin Pharmacother. 2002;3(6):657-669. [pmid: 12036405].
Gazzaruso C, Giordanetti S, De Amici E, et al. Relationship between erectile dysfunction and silent myocardial ischemia in apparently uncomplicated type 2 diabetic patients.[see comment]. Circulation. 2004;110(1):22-26. [pmid: 15210604].
Gazzaruso C, Pujia A, Solerte SB, et al. Erectile dysfunction and angiographic extent of coronary artery disease in type II diabetic patients. Int J Impot Res. 2006;18(3):311-315. [pmid: 16224493].
Gee WF, Holtgrewe HL, Albertsen PC, et al. Practice trends of American urologists in the treatment of impotence, incontinence and infertility. Br J Urol. 1996;156(5):1778-1780.
Gelbard MK, James K, Riach P, et al. Collagenase versus placebo in the treatment of Peyronie's disease: A double-blind study. Br J Urol. 1993;149(1):56-58.
Gelenberg AJ, Trivedi MH, Rush AJ, et al. Randomized, placebo-controlled trial of nefazodone maintenance treatment in preventing recurrence in chronic depression. Biol Psychiatry. 2003;54(8):806-817. [pmid: 14550680].
Gemery JM, Nangia AK, Mamourian AC, et al. Digital three-dimensional modelling of the male pelvis and bicycle seats: impact of rider position and seat design on potential penile hypoxia and erectile dysfunction. BJU Int. 2007;99(1):135-140. [pmid: 17227499].
George AJ. The actions and side effects of Anabolic Steroids in sport and social abuse. Andrologie. 2003;13(4):354-380.
George C, Grippat J, Safar M. Second line treatment of essential hypertension after beta-blockade. A randomised trial in 558 patients initially treated with bisoprolol 10mg. DRUG INVEST. 1990;2(3):150-154.
George VK, Erkhan S, Dhabuwala CB. Follow-up with Mentor two-piece inflatable penile prosthesis. Int J Impot Res. 1995;7(1):17-21. [pmid: 7670589].
George WH, Davis KC, Norris J, et al. Alcohol and erectile response: the effects of high dosage in the context of demands to maximize sexual arousal. Experimental & Clinical Psychopharmacology. 2006;14(4):461-470. [pmid: 17115874].
Gerber GS, Fitzpatrick JM. The role of a lipido-sterolic extract of Serenoa repens in the management of lower urinary tract symptoms associated with benign prostatic hyperplasia. BJU Int. 2004;94(3):338-344. [pmid: 15291864].
Gerber HR. Intrathecal morphine for chronic benign pain. Baillieres Best Practice & Research in Clinical Anaesthesiology. 2003;17(3):429-442.
Gerhard I, Roth B, Eggert-Kruse W, et al. Effects of kallikrein on sperm motility, capillary tube test, and pregnancy rate in an AIH program. Arch Androl. 1990;24(2):129-145. [pmid: 2327823].
Gerstenberg TC, Nordling J, Hald T, et al. Evaluation of patients with suspected neurogenic impotence. Neurourology & Urodynamics. 1990;9(2):216-217.
Ghanem H, Anis T. Preference studies are of value to the field of sexual medicine: Con. Current Sexual Health Reports. 2006;3(1):9-12.
Ghaziuddin Neera, Alessi Norman E. An open clinical trial of trazodone in aggressive children. J Child Adolesc Psychopharmacol. 1992;2(4):291-297. [pmid: 19630611].
Ghofrani HA, Osterloh IH, Grimminger F. Sildenafil: From angina to erectile dysfunction to pulmonary hypertension and beyond. Nat Rev Genet. 2006;5(8):689-702.
Ghofrani HA, Pepke-Zaba J, Barbera JA, et al. Nitric oxide pathway and phosphodiesterase inhibitors in pulmonary arterial hypertension. J Am Coll Cardiol. 2004;43(12 SUPPL.):68S-72S. [pmid: 15194181].
Ghofrani HA, Voswinckel R, Reichenberger F, et al. Differences in hemodynamic and oxygenation responses to three different phosphodiesterase-5 inhibitors in patients with pulmonary arterial hypertension: a randomized prospective study. J Am Coll Cardiol. 2004;44(7):1488-1496. [pmid: 15464333].
Gholami SS, Gonzalez-Cadavid NF, Lin CS, et al. Peyronie's disease: A review. Br J Urol. 2003;169(4):1234-1241.
Gholami SS, Rogers R, Chang J, et al. The effect of vascular endothelial growth factor and adeno-associated virus mediated brain derived neurotrophic factor on neurogenic and vasculogenic erectile dysfunction induced by hyperlipidemia. Br J Urol. 2003;169(4):1577-1581.
Giagulli VA, Carbone D. Hormonal control of inhibin B in men. J Endocrinol Invest. 2006;29(8):706-713. [pmid: 17033259].
Gibbons CH, Freeman R. Treatment options for autonomic neuropathies. Curr Treat Options Neurol. 2006;8(2):119-132. [pmid: 16464408].
Giembycz MA. Life after PDE4: Overcoming adverse events with dual-specificity phosphodiesterase inhibitors. Curr Opin Pharmacol. 2005;5(3 SPEC. ISS.):238-244. [pmid: 15907909].
Gilbert P, Sparwasser C, Beckert R, et al. Venous surgery in erectile dysfunction. The role of dorsal-penile-vein ligation and spongiosolysis for impotence. [Review] [26 refs]. Urol Int. 1992;49(1):40-47. [pmid: 1413325].
Gilbey SG. Neuropathy and foot problems in diabetes. Clin Med (Northfield Il). 2004;4(4):318-323.
Gillatt D. Antiandrogen treatments in locally advanced prostate cancer: Are they all the same?. Journal of Cancer Research & Clinical Oncology. 2006;132(SUPPL.1):S17-S26. [pmid: 16845534].
Gilling PJ, Kennett KM, Fraundorfer MR. Holmium laser resection v transurethral resection of the prostate: results of a randomized trial with 2 years of follow-up. J Endourol. 2000;14(9):757-760. [pmid: 11110572].
Gindin Leon, Resnicoff Diana Roberto, et al. Unconsummated marriages: A separate and different clinical entity. [References]. J Sex Marital Ther. 2002;28(Suppl1):85-99. [pmid: 11898713].
Gingell C. Use of intracavernosal alprostadil in erectile dysfunction. Hospital Medicine (London). 1998;59(10):777.
Ginsberg David L. Aripiprazole-induced recurrent priapism. [References]. Primary Psychiatry. 2006;13(11):28-29.
Giovannoni MP, Vergelli C, Biancalani C, et al. Novel pyrazolopyrimidopyridazinones with potent and selective phosphodiesterase 5 (PDE5) inhibitory activity as potential agents for treatment of erectile dysfunction. J Med Chem. 2006;49(17):5363-5371. [pmid: 16913726].
Giraldi A, Wyllie M, Wagner G. Abanoquil, a new alpha-1 adrenoceptor antagonist. In vitro and in vivo effect on erectile tissue. Int J Impot Res. 2000;12(Suppl 1):S37-S40.
Gitlin Michael J. Effects of depression and antidepressants on sexual functioning. Bull Menninger Clin. 1995;59(2):232-248. [pmid: 7795566].
Giuberti A, Manganini V, Picozzi SC, et al. Complete genital prosthetization in patients treated with bilateral orchiectomy for metachronous testicular cancer. Arch Ital Urol Androl. 2007;79(1):26-29. [pmid: 17484401].
Giuliano F. Editorial Comment on: Peripheral Mechanisms of Erectile Dysfunction in a Rat Model of Chronic Cocaine Use. Eur Urol 2007;
Giuliano F. Impact of medical treatments for benign prostatic hyperplasia on sexual function. [Review] [23 refs]. BJU Int. 2006;97(Suppl 2):34-38. [pmid: 16507052].
Giuliano F, Allard J. Apomorphine SL (Uprima): Preclinical and clinical experiences learned from the first central nervous system-acting ED drug. Int J Impot Res. 2002;14(SUPPL. 1):S53-S56. [pmid: 11850736].
Giuliano F, Clement P. Serotonin and Premature Ejaculation: From Physiology to Patient Management. Eur Urol. 2006;50(3):454-466. [pmid: 16844284].
Giuliano F, Hultling C, El Masry W S et al. Sildenafil citrate (VIAGRA): a novel oral treatment for erectile dysfunction caused by traumatic spinal cord injury. Int J Clin Pract 1999;Supplement.102–106.
Giuliano F, Kaplan SA, Cabanis MJ, et al. Hemodynamic interaction study between the alpha1-blocker alfuzosin and the phosphodiesterase-5 inhibitor tadalafil in middle-aged healthy male subjects. Urology. 2006;67(6):1199-1204. [pmid: 16765179].
Giuliano Francois, Rampin Olivier, et al. Neural control of erection. [References]. Physiol Behav. 2004;83(2):189-201. [pmid: 15488539].
Gjertson CK, Walmsley K, Kaplan SA. Benign prostatic hyperplasia: Now we can begin to tailor treatment. Cleve Clin J Med. 2004;71(11):857-880. [pmid: 15570735].
Gladstone David. Review of Madhouse: A Tragic Tale of Megalomania and Modern Medicine. Hist Psychiatry. 2006;17(4):499-500.
Gleave M, Evans CP. What's hot in the prostate?. Prostate Cancer & Prostatic Diseases. 2003;6(4):268-271. [pmid: 14663465].
Gleave M, Qian J, Andreou C, et al. The effects of the dual 5a-reductase inhibitor dutasteride on localized prostate cancer - Results from a 4-month pre-radical prostatectomy study. Prostate Suppl. 2006;66(15):1674-1685.
Glick HA, McCarron TJ, Althof SE, et al. Construction of scales for the Center for Marital and Sexual Health (CMASH) Sexual Functioning Questionnaire. J Sex Marital Ther. 1997;23(2):103-117. [pmid: 9230491].
Glimelius B, Steineck G. Low evidence of radiation therapy in prostate cancer: A plea for intensified scientific activity. Acta Oncol (Madr). 2004;43(4):311-315.
Glina S. Testosterone and erectile dysfunction. The Journal of Mens Health & Gender. 2004;1(4):407-412.
Glina S, Silva MF, Puech-Leao P, et al. Veno-occlusive dysfunction of corpora cavernosa: comparison of diagnostic methods. Int J Impot Res. 1995;7(1):1-10. [pmid: 7670587].
Goadsby PJ. Recent advances in the diagnosis and management of migraine. Br Med J. 2006;332(7532):25-29. [pmid: 16399733].
Godschalk MF, Unice KA, Bergner D, et al. A trial study: The effect of low dose human chorionic gonadotropin on the symptoms of benign prostatic hyperplasia. Br J Urol. 2003;170(4 I):1264-1269.
Goetz LL, Stiens SA. Abdominal electric stimulation facilitates penile vibratory stimulation for ejaculation after spinal cord injury: a single-subject trial. Archives of Physical Medicine & Rehabilitation. 2005;86(9):1879-1883. [pmid: 16181958].

## Review

Alboni P, Bettiol K, Fuca G, et al. Sexual activity with and without the use of sildenafil: risk of cardiovascular events in patients with heart disease. [Review] [41 refs]. Italian Heart Journal: Official Journal of the Italian Federation of Cardiology. 2004;5(5):343-349. [pmid: 15185897].
Alexander WD. The diabetes physician and an assessment and treatment programme for male erectile impotence. Diabet Med. 1990;7(6):540-543. [pmid: 2142058].
Althof Stanley E, Seftel Allen D. The evaluation and management of erectile dysfunction. Psychiatr Clin North Am. 1995;18(1):171-192. [pmid: 7761304].
Altwein JE, Thon WF. Oral treatment of erectile dysfunction: Background, spectrum and limitations. Aktuel Urol. 1999;30(7):449-460.
Anderson PCB, Gommersall L, Hayne D, et al. New phosphodiesterase inhibitors in the treatment of erectile dysfunction. Expert Opin Pharmacother. 2004;5(11):2241-2249. [pmid: 15500370].
Anderson TR, Goldberg JF, Harrow M. A review of medication side effects and treatment adherence in bipolar disorder. Primary Psychiatry. 2004;11(9):48-54.
Andersson KE, Schroder A. Therapeutic strategies for drug treatment of stress urinary incontinence. Drug Discovery Today: Therapeutic Strategies. 2004;1(2):259-265.
Anonymous. New oral drugs for erectile dysfunction. [Review][21 refs]. Drug & Therapeutics Bulletin 2004;42(7):49–52.
Anonymous. Oral agents are successful in the treatment of erectile dysfunction in patients with cardiovascular disease. Drugs & Therapy Perspectives 2005;21(6):
Anonymous. Phosphodiesterase type 5 (PDE5) inhibitors: Looking beyond erectile dysfunction. British Journal of Cardiology 2003;10(SUPPL. 4):S1-S8.
Anonymous. In erectile disorders: A narrow therapeutic margin. Prescrire Int 2002;11(59):76–79.
Anonymous. Tadalafil. Slightly more convenient, but poorly assessed in organic disorders. Prescrire Int 2003;12(68):213–215.
Anonymous. Sildenafil and erectile dysfunction. Helpful. Prescrire Int 1998;7(38):163–165.
Archer SL, Gragasin FS, Webster L, et al. Aetiology and management of male erectile dysfunction and female sexual dysfunction in patients with cardiovascular disease. Drugs Aging. 2005;22(10):823-844. [pmid: 16245957].
Ashton AK, D'Mello DA, Dantz B, et al. Treatment regimens for managing depression in family practice. J Fam Pract. 2003;52(SUPPL.):S48-S60. [pmid: 14693078].
Atala A, Amin M. Current concepts in the treatment of genitourinary tract disorders in the older individual. [Review] [87 refs]. Drugs Aging. 1991;1(3):176-193. [pmid: 1724398].
Aung HH, Dey L, Rand V, et al. Alternative therapies for male and female sexual dysfunction. Am J Chin Med. 2004;32(2):161-173. [pmid: 15315255].
Aversa A, Bruzziches R, Spera G. A rationale for the use of testosterone ‘salvage’ in treatment of men with erectile dysfunction failing phosphodiesterase inhibitors. Endocr Pract. 2005;15(2):99-105.
Aversa A, Pili M, Fabbri A, et al. Erectile dysfunction: Expectations beyond phosphodiesterase Type 5 inhibition. J Endocrinol Invest. 2004;27(2):192-206. [pmid: 15129818].
Bain J. Epidemiology, evaluation and diagnosis of andropause. Geriatrics and Aging. 2003;6(10 SUPPL.):4-8.
Baldwin DS. Sexual dysfunction associated with antidepressant drugs. [Review] [96 refs]. Expert Opin Drug Saf. 2004;3(5):457-470. [pmid: 15335301].
Bancroft J. A history of sexual medicine in the United Kingdom. Br J Sex Med. 2005;2(4):569-574.
Basu A, Ryder RE. New treatment options for erectile dysfunction in patients with diabetes mellitus. [Review] [88 refs]. Drugs. 2004;64(23):2667-2688. [pmid: 15537369].
Beckman TJ, Mynderse LA. Evaluation and medical management of benign prostatic hyperplasia. Mayo Clin Proc. 2005;80(10):1356-1362. [pmid: 16212149].
Beckman TJ, bu-Lebdeh HS, Mynderse LA. Evaluation and medical management of erectile dysfunction. [Review] [34 refs]. Mayo Clin Proc. 2006;81(3):385-390. [pmid: 16529142].
Bella AJ, Brock GB. Tadalafil in the treatment of erectile dysfunction. [Review] [32 refs]. Curr Urol Rep. 2003;4(6):472-478. [pmid: 14622501].
Bella AJ, Brock GB. Intracavernous pharmacotherapy for erectile dysfunction. Endocrine. 2004;23(23):149-155. [pmid: 15146094].
Bella AJ, Brant WO, Brock GB. Contemporary intracavernous pharmacotherapy for erectile dysfunction in the aging male. Aging Health. 2006;2(4):559-570.
Bellinghieri G, Santoro D, Lo Forti B, et al. Erectile dysfunction in uremic dialysis patients: Diagnostic evaluation in the sildenafil era. Am J Kidney Dis. 2001;38(4 SUPPL. 1):S115-S117. [pmid: 11576935].
Bernstein AJ, Peters KM. Expanding indications for neuromodulation. Urol Clin North Am. 2005;32(1):59-63. [pmid: 15698877].
Beutel M. Psychosomatic aspects in the diagnosis and treatment of erectile dysfunction. [Review] [40 refs]. Andrologia. 1999;31(Suppl 1):37-44. [pmid: 10643518].
Bhugra D, Crowe M. Physical treatments of erectile disorders. Int Rev Psychiatry. 1995;7(2):217-223.
Blanker Marco H, Verhagen Arianne P. Lipid-lowering drugs and erectile dysfunction. [References]. Fam Pract. 2002;19(5):567. [pmid: 12356716].
Brant WO, Bella AJ, Lue TF. Erectile and sexual dysfunction in the aging diabetic male. Aging Health. 2006;2(6):1025-1034.
Briganti A, Salonia A, Gallina A, et al. Emerging oral drugs for erectile dysfunction. [Review] [83 refs]. Expert Opinion on Emerging Drugs. 2004;9(1):179-189. [pmid: 15155143].
Brock G. Oral agents: First-line therapy for erectile dysfunction. European Urology Supplements. 2002;1(8):12-18.
Brock G B. Tadalafil: a new agent for erectile dysfunction. [Review][12 refs]. Can J Urol 2003;10Suppl-22.
Brock GB, Bochinski D. Modern pharmacotherapy for erectile dysfunction: evolving concepts with central and peripheral acting agents. [Review] [40 refs]. Curr Opin Urol. 2001;11(6):625-630. [pmid: 11734700].
Brock GB, Lue TF. Drug-induced male sexual dysfunction. An update. [Review] [88 refs]. Drug Saf. 1993;8(6):414-426. [pmid: 8329147].
Broderick GA. Intracavernous pharmacotherapy: Treatment for the aging erectile response. Urol Clin North Am. 1996;23(1):111-126. [pmid: 8677530].
Broderick GA. Changing practice patterns in erectile dysfunction: a diagnostic algorithm for the new millennium. [Review] [42 refs]. Adv Ren Replace Ther. 1999;6(4):314-326. [pmid: 10543711].
Broderick GA. Evidence based assessment of erectile dysfunction. [Review] [62 refs]. Int J Impot Res. 1998;10(Suppl 2):S64-S73. [pmid: 9647964].
Brotons FB, Campos JC, Gonzalez-Correales R, et al. Core document on erectile dysfunction: Key aspects in the care of a patient with erectile dysfunction. Int J Impot Res. 2004;16(SUPPL. 2):S26-S39. [pmid: 15496854].
Burnett A L. Phosphodiesterase 5 mechanisms and therapeutic applications. Am J Cardiol 2005;96(12 SUPPL. 2):
Burns-Cox N, Gingell C. Medical treatment of erectile dysfunction. [Review] [64 refs]. Postgrad Med J. 1998;74(872):336-342. [pmid: 9799886].
Butler RN, Lewis MI, Hoffman E, et al. Love and sex after 60: how to evaluate and treat the impotent older man. A roundtable discussion: Part 2.[see comment]. Geriatrics. 1994;49(10):27-32. [pmid: 7926846].
Buvat J. Androgen therapy with dehydroepiandrosterone. [Review] [89 refs]. World J Urol. 2003;21(5):346-355. [pmid: 14551720].
Carbone DJ, Seftel AD. Erectile dysfunction. Diagnosis and treatment in older men. [Review] [33 refs]. Geriatrics. 2002;57(9):18-24. [pmid: 12271825].
Carrier S. Pharmacology of phosphodiesterase 5 inhibitors. [Review][21 refs]. Can J Urol 2003;10Suppl-6.
Carrier S, Zvara P, Lue TF. Erectile dysfunction. Endocrinology & Metabolism Clinics of North America. 1994;23(4):773-782. [pmid: 7705319].
Carson C C. Cardiac safety in clinical trials of phosphodiesterase 5 inhibitors. Am J Cardiol 2005;96(12 SUPPL. 2):
Carson CC. Erectile dysfunction: Evaluation and new treatment options. Psychosom Med. 2004;66(5):664-671. [pmid: 15385689].
Carson CC. Long-term use of sildenafil. Expert Opin Pharmacother. 2003;4(3):397-405. [pmid: 12614192].
Carson CC. Penile prosthesis implantation: surgical implants in the era of oral medication. [Review] [36 refs]. Urol Clin North Am. 2005;32(4):503-509. [pmid: 16291041].
Carson CC. Oral and injectable medications for the treatment of erectile dysfunction. [Review] [54 refs]. Curr Urol Rep. 2000;1(4):307-312. [pmid: 12084309].
Carson CC, Lue TF. Phosphodiesterase type 5 inhibitors for erectile dysfunction. BJU Int. 2005;96(3):257-280. [pmid: 16042713].
Carson CC. Cardiac safety in clinical trials of phosphodiesterase 5 inhibitors. [Review] [25 refs]. Am J Cardiol. 2005;96(12B):37M-41M.
Carson CC, Hubbard JS, Wallen E. Erectile dysfunction and treatment of carcinoma of the prostate. [Review] [52 refs]. Curr Urol Rep. 2005;6(6):461-469. [pmid: 16238921].
Carson CC, Porst Nehra, Althof Meuleman. Erectile dysfunction in the 21st century: Whom we can treat, whom we cannot treat and patient education. Int J Impot Res. 2002;14(SUPPL. 1):S29-S34. [pmid: 11850732].
Carson C, Giuliano F, Goldstein I, et al. The ‘effectiveness’ scale—therapeutic outcome of pharmacologic therapies for ED: an international consensus panel report. [Review] [7 refs]. Int J Impot Res. 2004;16(3):207-213. [pmid: 15164088].
Champion HC. Erectile dysfunction and cardiovascular disease: Carrots, sticks, and better men's health. Advanced Studies in Medicine. 2006;6(4):163-170.
Chandra Singh J, Devasia A, Gnanaraj L, et al. Erectile dysfunction. Natl Med J India. 2005;18(3):139-143. [pmid: 16130616].
Chaudhuri A, Wiles P. Optimal treatment of erectile failure in patients with diabetes. [Review] [42 refs]. Drugs. 1995;49(4):548-554. [pmid: 7789288].
Cheitlin MD. Should the patient with coronary artery disease use sildenafil?. [Review] [25 refs]. Prev Cardiol. 2003;6(3):161-165. [pmid: 15319586].
Cheitlin MD. Sexual activity and cardiovascular disease. Am J Cardiol. 2003;92(9 SUPPL. 1):3M-8M.
Chew KK. Intracavernosal injection therapy. Does it still have a role in erectile dysfunction?. [Review] [21 refs]. Aust Fam Physician. 2001;30(1):43-46. [pmid: 11211711].
Chu NV, Edelman SV. Erectile dysfunction and diabetes. [Review] [32 refs]. Curr Diab Rep. 2002;2(1):60-66. [pmid: 12643124].
Corbin JD, Francis SH, Webb DJ. Phosphodiesterase type 5 as a pharmacologic target in erectile dysfunction. Urology. 2002;60(2 SUPPL. 2):4-11. [pmid: 12414329].
Costabile RA. Transurethral therapy for the treatment of erectile dysfunction: Infant or dinosaur?. Mol Urol. 1999;3(2):135-139. [pmid: 10851315].
Costabile RA. Alprostadil for the treatment of erectile dysfunction. Expert Opin Investig Drugs. 1999;8(6):877-884.
Cournoyer Barry. Male erectile difficulty: Crisis intervention and short-term treatment. Roberts, Albert R (Ed) 1990;(1990):treatment-278.
Courtois FJ, Charvier KF, Leriche A, et al. Clinical approach to erectile dysfunction in spinal cord injured men. A review of clinical and experimental data. [Review] [60 refs]. Paraplegia. 1995;33(11):628-635. [pmid: 8584296].
Crum NF, Furtek KJ, Olson PE, et al. A review of hypogonadism and erectile dysfunction among HIV-infected men during the pre- and post-HAART eras: Diagnosis, pathogenesis, and management. AIDS Patient Care & Stds. 2005;19(10):655-671. [pmid: 16232050].
Cummings MH. The impact of erectile dysfunction and its treatment with phosphodiesterase type-5 (PDE5) inhibitors in patients with diabetes. Practical Diabetes International. 2004;21(6):225-230.
Dal Piaz V, Castellana MC, Vergelli C, et al. Synthesis and evaluation of some pyrazolo[3,4-d]pyridazinones and analogues as PDE 5 inhibitors potentially useful as peripheral vasodilator agents. Journal of Enzyme Inhibition & Medicinal Chemistry. 2002;17(4):227-233. [pmid: 12530475].
Davidson Julian M, Rosen Raymond C. Hormonal determinants of erectile function. Rosen, Raymond C (Ed); Leiblum, Sandra Risa (Ed) 1992;(1992):378
DeWire DM. Evaluation and treatment of erectile dysfunction. [Review] [35 refs]. Am Fam Physician. 1996;53(6):2101-2108. [pmid: 8623722].
Dinsmore W. Treatment of erectile dysfunction. Int J STD AIDS. 2004;15(4):215-221. [pmid: 15075013].
Dinsmore WW. Available and future treatments for erectile dysfunction. [Review] [23 refs]. Clin Cornerstone. 2005;7(1):37-45. [pmid: 16156422].
DiSanto ME. Contractile mechanisms in diabetes-related erectile dysfunction. Curr Pharm Des. 2005;11(31):3995-4010. [pmid: 16378506].
Doggrell S. Do vardenafil and tadalafil have advantages over sildenafil in the treatment of erectile dysfunction?. Int J Impot Res. 2007;19(3):281-295. [pmid: 17183346].
Douglass MA, Lin JC. Update on the treatment of benign prostatic hyperplasia. Hosp Formul. 2005;40(2):50-64.
Droupy S, Ponsot Y, Giuliano F. How, why and when should urologists evaluate male sexual function?. Nature Clinical Practice Urology. 2006;3(2):84-94. [pmid: 16470207].
Duckworth K. Running an erectile dysfunction clinic.[see comment]. Pap Natl Conf Prof Nurses Physicians. 1997;12(11):775-778.
Dunsmuir WD, Holmes SA. The aetiology and management of erectile, ejaculatory, and fertility problems in men with diabetes mellitus. [Review] [96 refs]. Diabet Med. 1996;13(8):700-708. [pmid: 8862943].
Eardley I. Vardenafil: a new oral treatment for erectile dysfunction. [Review] [20 refs]. Int J Clin Pract. 2004;58(8):801-806. [pmid: 15372854].
Eardley I, Cartledge J. Tadalafil (Cialis) for men with erectile dysfunction.[see comment]. Int J Clin Pract. 2002;56(4):300-304. [pmid: 12074215].
Ebert T. Clinical experiences with testosterone therapy: Prostate safety. Aging Male. 2004;7(4):304-311. [pmid: 15799126].
Ebert T, Jockenhovel F, Morales A, et al. The current status of therapy for symptomatic late-onset hypogonadism with transdermal testosterone gel. Eur Urol. 2005;47(2):137-146. [pmid: 15661407].
Eid J F. Sildenafil citrate: current clinical experience. [Review][19 refs]. Int J Impot Res 2000;12Suppl-6.
Eilenberg KL, Hoover AM, Rutherford ML, et al. From informed consent through database lock: An interactive clinical trial conducted using the internet. Drug Inf J. 2004;38(3):239-251.
Emmick JT, Stuewe SR, Mitchell M. Overview of the cardiovascular effects of tadalafil. Eur Heart J Suppl. 2002;4(H):H32-H47.
Everaerd Walter. Male erectile disorder. O'Donohue, William (Ed); Geer, James H (Ed) 1993;(1993):418
Fabbri A, Aversa A, Isidori A. Erectile dysfunction: An overview. Hum Reprod Update. 1997;3(5):455-466. [pmid: 9528911].
Fagan Peter. Psychogenic impotence in relatively young men. Levine, Stephen B (Ed); Risen, Candace B (Ed); Althof, Stanley E (Ed) 2003;(2003):473-Routledge.
Fazio L, Brock G. Erectile dysfunction: Management update. CMAJ: Canadian Medical Association Journal. 2004;170(9):1429-1437. [pmid: 15111479].
Feret B. Apomorphine: A sublingual dopamine agonist for the treatment of erectile dysfunction. Hosp Formul. 2000;35(7):573-579.
Ferrario CM, Levy P. Sexual dysfunction in patients with hypertension: implications for therapy. [Review] [49 refs]. J Clin Hypertens. 2002;4(6):424-432.
Foreman Mark M, Doherty Paul C. Experimental approaches for the development of pharmacological therapies for erectile dysfunction. Riley, Alan J (Ed); Peet, Malcolm (Ed); Wilson, Catherine (Ed) 1993;(1993):235
Fricker J. The rise and fall of Viagra. Drug Discov Today. 2001;6(14):704-706. [pmid: 11445454].
Galle G, Trummer H. The etiology of erectile dysfunction and mechanisms by which drugs improve erection. Med Actual. 2003;39(3):193-201.
Garber B. Inflatable penile prostheses for the treatment of erectile dysfunction. Expert Review of Medical Devices. 2005;2(3):341-350. [pmid: 16288597].
Garcia-Reboll L, Mulhall JP, Goldstein I. Drugs for the treatment of impotence. [Review] [98 refs]. Drugs Aging. 1997;11(2):140-151. [pmid: 9259177].
Gerber HR. Intrathecal morphine for chronic benign pain. Baillieres Best Practice & Research in Clinical Anaesthesiology. 2003;17(3):429-442.
Ghofrani HA, Pepke-Zaba J, Barbera JA, et al. Nitric oxide pathway and phosphodiesterase inhibitors in pulmonary arterial hypertension. J Am Coll Cardiol. 2004;43(12 SUPPL.):68S-72S. [pmid: 15194181].
Gingell C. Use of intracavernosal alprostadil in erectile dysfunction. Hospital Medicine (London). 1998;59(10):777.
Gingell JC. New developments in self-injection therapy for erectile dysfunction. [Review] [33 refs]. Br J Urol. 1998;81(4):599-603. [pmid: 9598634].
Gitlin Michael J. Effects of depression and antidepressants on sexual functioning. Bull Menninger Clin. 1995;59(2):232-248. [pmid: 7795566].
Giuliano F. Apomorphine SL: Evolution of a centrally acting treatment for erectile dysfunction. European Urology Supplements. 2002;1(3):1-3.
Giuliano F. Phosphodiesterase type 5 inhibition in erectile dysfunction: An overview. Eur Heart J Suppl. 2002;4(H):H7-H12.
Giuliano F, Varanese L. Tadalafil: A novel treatment for erectile dysfunction. Eur Heart J Suppl. 2002;4(H):H24-H31.
Gjertson CK, Walmsley K, Kaplan SA. Benign prostatic hyperplasia: Now we can begin to tailor treatment. Cleve Clin J Med. 2004;71(11):857-880. [pmid: 15570735].
Gleave M, Evans CP. What's hot in the prostate?. Prostate Cancer & Prostatic Diseases. 2003;6(4):268-271. [pmid: 14663465].
Glina S. Testosterone and erectile dysfunction. The Journal of Mens Health & Gender. 2004;1(4):407-412.
Godschalk MF, Sison A, Mulligan T. Diagnosis and therapy of erectile dysfunction. Med Actual. 1997;33(7):475-483.
Godschalk Michael F, Sison Alfredo, Mulligan Thomas. Management of erectile dysfunction by the geriatrician. J Am Geriatr Soc. 1997;45(10):1240-1246. [pmid: 9329488].
Goldenberg MM. Pharmaceutical-approval update. P & T. 2005;30(7):414-415.
Goldstein I. A clinical paradigm for the combined management of androgen insufficiency and erectile dysfunction. Endocrinol Metab Clin North Am. 2007;36(2):435-452. [pmid: 17543728].
Goldstein I, Carson C, Rosen R, et al. Vasomax for the treatment of male erectile dysfunction. World J Urol. 2001;19(1):51-56. [pmid: 11289571].
Goldstein Irwin. Diagnosis of erectile dysfunction. Sex Disabil. 2004;22(2):121-130.
Gontero P, Kirby R. Proerectile pharmacological prophylaxis following nerve-sparing radical prostatectomy (NSRP). Prostate Cancer & Prostatic Diseases. 2004;7(3):223-226. [pmid: 15249931].
Gonzalez RR, Kaplan SA. Tadalafil for the treatment of lower urinary tract symptoms in men with benign prostatic hyperplasia. [Review] [36 refs]. Expert Opinion On Drug Metabolism & Toxicology. 2006;2(4):609-617. [pmid: 16859408].
Gonzalez-Cadavid NF, Rajfer J. Mechanisms of, and novel pharmacological approaches to, Peyronie's disease. Drug Discovery Today: Disease Mechanisms. 2004;1(1):99-104.
Gonzalez-Cadavid NF, Rajfer J. Therapy of erectile dysfunction: Potential future treatments. Endocrine. 2004;23(23):167-176. [pmid: 15146097].
Gooren LJG, Saad F. Recent insights into androgen action on the anatomical and physiological substrate of penile erection. Asian J Androl. 2006;8(1):3-9. [pmid: 16372114].
Graber Benjamin. Medical aspects of sexual arousal disorders. O'Donohue, William (Ed); Geer, James H (Ed) 1993;(1993):418
Graul AI. The year's new drugs. Drug News Perspect. 2003;16(1):22-39. [pmid: 12682669].
Greco EA, Spera G, Aversa A. Combining testosterone and PDE5 inhibitors in erectile dysfunction: basic rationale and clinical evidences.[see comment]. [Review] [53 refs]. Eur Urol. 2006;50(5):940-947. [pmid: 16979814].
Gregoire Alain. New treatments for erectile impotence. Br J Psychiatry Suppl. 1992;160(Mar.):315-326.
Greiner KA, Weigel JW. Erectile dysfunction.[see comment]. Am Fam Physician. 1996;54(5):1675-1682. [pmid: 8857789].
Grossman A, Barenboim E, Azaria B, et al. Oral drug therapy for erectile dysfunction: Overview and aeromedical implications. Aviation Space & Environmental Medicine. 2004;75(11):997-1000.
Guay AT. Lecture 5: Sexual dysfunction in the diabetic patient. Int J Impot Res. 2001;13(SUPPL. 5):S47-S50. [pmid: 11781748].
Guay A T. Erectile dysfunction. Are you prepared to discuss it?. [Review][12 refs]. Postgrad Med 133;97(4):127–130.
Guirguis Waguih. Oral treatment of erectile dysfunction: From herbal remedies to designer drugs. J Sex Marital Ther. 1998;24(2):69-73. [pmid: 9611686].
Guirguis Waguih R. The problem of the single impotent man. Int Rev Psychiatry. 1995;7(2):191-194.
Gupta M, Kovar A, Meibohm B. The clinical pharmacokinetics of phosphodiesterase-5 inhibitors for erectile dysfunction. J Clin Pharmacol. 2005;45(9):987-1003. [pmid: 16100293].
Hackett GI. Patient preferences in treatment of erectile dysfunction: The continuing importance of patient education. Clin Cornerstone. 2005;7(1):57-64. [pmid: 16156424].
Hafez ES, Hafez SD. Erectile dysfunction: anatomical parameters, etiology, diagnosis, and therapy. [Review] [59 refs]. Arch Androl. 2005;51(1):15-31. [pmid: 15764414].
Hafron J, Christ GJ. Novel therapeutic strategies for the treatment of erectile dysfunction. Drug Discovery Today: Therapeutic Strategies. 2004;1(2):249-257.
Hale TM, Hannan JL, Heaton JPW, et al. Common therapeutic strategies in the management of sexual dysfunction and cardiovascular disease. Current Drug Targets - Cardiovascular & Haematological Disorders. 2005;5(2):185-195. [pmid: 15853758].
Hall MC. Management of erectile dysfunction after radical prostatectomy. [Review] [46 refs]. Semin Urol Oncol. 1995;13(3):215-223. [pmid: 8521135].
Handelsman DJ, Liu PY. Andropause: Invention, prevention, rejuvenation. Trends in Endocrinology & Metabolism. 2005;16(2):39-45. [pmid: 15734143].
Handelsman H. Diagnosis and treatment of impotence. [Review][171 refs]. Health Technol Assess Rep 1990;(2):1–23.
Harvey Kenneth V, Balon Richard. Clinical implications of antidepressant drug effects on sexual function. Ann Clin Psychiatry. 1995;7(4):189-201. [pmid: 8721893].
Hatch JP. Psychophysiological aspects of sexual dysfunction. [Review] [88 refs]. Arch Sex Behav. 1981;10(1):49-64. [pmid: 7011254].
Hatzichristou DG, Pescatori ES. Current treatments and emerging therapeutic approaches in male erectile dysfunction. BJU International - Supplement. 2001;88(3):11-17.
Hatzimouratidis K, Hatzichristou DG. Treatment options for erectile dysfunction in patients failing oral drug therapy. Eau Update Series. 2004;2(2):75-83.
Hayes A, Kochar MS. Erectile dysfunction in patients with hypertension: Management tactics. Consultant. 2004;44(12):1534-1540.
Heaton J P. Apomorphine: an update of clinical trial results. Int J Impot Res 2000;12Suppl-73.
Heaton JPW. Characterising the benefit of apomorphine SL (Uprima) as an optimised treatment for representative populations with erectile dysfunction. Int J Impot Res. 2001;13(SUPPL. 3):S35-S39. [pmid: 11477490].
Hedelin H, Stroberg P. Treatment for erectile dysfunction based on patient-reported outcomes: To every man the PDE5 inhibitor that he finds superior. Drugs. 2005;65(16):2245-2251. [pmid: 16266193].
Hedlund H, Hedlund P. Pharmacotherapy in erectile dysfunction agents for self-injection programs and alternative application models. [Review] [78 refs]. Scandinavian Journal of Urology & Nephrology Supplementum. 1996;179:129-138. [pmid: 8908679].
Herschorn S. Cardiovascular safety of PDE5 inhibitors. [Review][15 refs]. Can J Urol 2003;10Suppl-8.
Heyns CF. Triptorelin in the treatment of prostate cancer: Clinical efficacy and tolerability. Am J Cancer. 2005;4(3):169-183.
Hijazi RA, Cunningham GR. Andropause: is androgen replacement therapy indicated for the aging male?. [Review] [123 refs]. Annu Rev Med. 2005;56:117-137. [pmid: 15660505].
Hijazi RA, Betancourt-Albrecht M, Cunningham GR. Gonadal and erectile dysfunction in diabetics. Med Clin North Am. 2004;88(4):933-945. [pmid: 15308386].
Hirooka Y, Shimokawa H. Therapeutic potential of rho-kinase inhibitors in cardiovascular diseases. [Review] [76 refs]. American Journal of Cardiovascular Drugs. 2005;5(1):31-39. [pmid: 15631536].
Hood S, Kirby M. PDE-5 inhibitors - A summary. British Journal of Diabetes & Vascular Disease. 2004;4(6):383-386.
Hood S, Kirby M. Risk factor assessment of erectile dysfunction. British Journal of Diabetes & Vascular Disease. 2004;4(3):157-161.
Howes L, Martin J, Kritharides L. Diltiazem-mediated inhibition of sildenafil metabolism may promote nitrate-induced hypotension [1] (multiple letters). Intern Med J. 2001;31(6):373-375. [pmid: 11529595].
Hutter AM. Role of the Cardiologist: Clinical Aspects of Managing Erectile Dysfunction. Clin Cardiol. 2004;27(4 SUPPL.):I3-I7. [pmid: 15115189].
Incrocci L. Radiotherapeutic treatment of Peyronie's disease. Expert Review of Pharmacoeconomics & Outcomes Research. 2004;4(2):235-242. [pmid: 19807528].
Incrocci L, Slob AK, Levendag PC. Sexual (dys)function after radiotherapy for prostate cancer: a review. [Review] [131 refs]. Int J Radiat Oncol Biol Phys. 2002;52(3):681-693. [pmid: 11849790].
Intili H. Factors in predicting initial in-office therapeutic dosages of alprostadil for the treatment of organic impotence. Urol Nurs. 1998;18(2):111-113. [pmid: 9866639].
Jackson G. Phosphodiesterase type 5 inhibition in cardiovascular disease: Experimental models and potential clinical applications. Eur Heart J Suppl. 2002;4(H):H19-H23.
Jackson G, Gillies H, Osterloh I. Past, present, and future: a 7-year update of Viagra (sildenafil citrate). [Review] [128 refs]. Int J Clin Pract. 2005;59(6):680-691. [pmid: 15924597].
Jannini EA, Lenzi A, Wagner G. New perspectives in the pharmacotherapy of erectile dysfunction. IDrugs. 2003;6(12):1165-1172. [pmid: 14666427].
Jeon YH, Heo YS, Kim CM, et al. Phosphodiesterase: Overview of protein structures, potential therapeutic applications and recent progress in drug development. Cellular & Molecular Life Sciences. 2005;62(11):1198-1220. [pmid: 15798894].
Jiang W, Guan J, Macielag MJ, et al. Pyrroloquinolone PDE5 inhibitors with improved pharmaceutical profiles for clinical studies on erectile dysfunction. J Med Chem. 2005;48(6):2126-2133. [pmid: 15771456].
Jin L, Linder AE, Mills TM, et al. Inhibition of the tonic contraction in the treatment of erectile dysfunction. Expert Opin Ther Targets. 2003;7(2):265-276. [pmid: 12667102].
Jnnemann KP. How effective are PDE-S inhibitors?. Journal fur Urologie und Urogynakologie. 2003;10(4):16-19.
Jockenhovel F. Testosterone therapy - What, when and to whom?. Aging Male. 2004;7(4):319-324. [pmid: 15799128].
Johansen KL. Treatment of hypogonadism in men with chronic kidney disease. Advances in Chronic Kidney Disease. 2004;11(4):348-356. [pmid: 15492971].
Kalsi JS, Kell PD. Update on oral treatments for male erectile dysfunction. [Review] [53 refs]. Journal of the European Academy of Dermatology & Venereology. 2004;18(3):267-274. [pmid: 15096134].
Kalsi JS, Bahadur G, Muneer A, et al. Novel PDE5 inhibitors for the treatment of male erectile dysfunction. Reprod Biomed Online. 2003;7(4):456-461. [pmid: 14656408].
Kantor J, Bilker WB, Glasser DB, et al. Prevalence of erectile dysfunction and active depression: an analytic cross-sectional study of general medical patients. Am J Epidemiol. 2002;156(11):1035-1042. [pmid: 12446260].
Kaplan SA. Editorial: Benign prostatic hyperplasia management - Statistical significance may not translate into clinical relevance. Br J Urol. 2004;171(3):1207-1208.
Kaufman JM. The effect of androgen supplementation therapy on the prostate. Aging Male. 2003;6(3):166-174. [pmid: 14628497].
Kaufman JM, Vermeulen A. The decline of androgen levels in elderly men and its clinical and therapeutic implications. Endocr Rev. 2005;26(6):833-876. [pmid: 15901667].
Kendirci M, Hellstrom WJG. Current concepts in the management of erectile dysfunction in men with prostate cancer. Clinical Prostate Cancer. 2004;3(2):87-92. [pmid: 15479491].
Kendirci M, Bejma J, Hellstrom WJG. Update on erectile dysfunction in prostate cancer patients. Curr Opin Urol. 2006;16(3):186-195. [pmid: 16679857].
Kendirci M, Walls MM, Hellstrom WJ. Central nervous system agents in the treatment of erectile dysfunction. [Review] [137 refs]. Urol Clin North Am. 2005;32(4):487-501. [pmid: 16291040].
Khan MA, Mikhailidis DP, Morgan RJ. Sildenafil: A urologist's view. Current Medical Research & Opinion, Supplement. 1999;16(1):s48-s58.
Khan MA, Thompson CS, Sullivan ME, et al. The role of prostaglandins in the aetiology and treatment of erectile dysfunction. [Review] [83 refs]. Prostaglandins Leukotrienes & Essential Fatty Acids. 1999;60(3):169-174.
Kim S, Narayanan S, Song JC. Tadalafil: An oral selective phosphodiesterase 5 inhibitor for treatment of erectile dysfunction. Hosp Formul. 2002;37(6):289-296.
Kim YC, Yoo M, Lee MG. DA-8159: Erectogenic. Drugs of the Future. 2005;30(7):678-682.
Kirby M. Management of erectile dysfunction in men with cardiovascular conditions. British Journal of Cardiology. 2003;10(4):305-307.
Kirby M, Kirby R. The management of hypertension in patients with benign prostatic hyperplasia and erectile dysfunction. British Journal of Cardiology. 2005;12(2):107-116.
Kloner R. Erectile dysfunction and hypertension. Int J Impot Res. 2007;19(3):296-302. [pmid: 17151696].
Kloner R A. Sex and the patient with cardiovascular risk factors: focus on sildenafil. [Review][37 refs]. Am J Med 2000;109Suppl-21S.
Kloner RA. Novel Phosphodiesterase Type 5 Inhibitors: Assessing Hemodynamic Effects and Safety Parameters. Clin Cardiol. 2004;27(4 SUPPL.):I20-I25. [pmid: 15115192].
Kloner RA. Erectile dysfunction and cardiovascular risk factors. Hospital Practice (Office Edition). 2001;36(8):41-51.
Kloner R A. Pharmacology and drug interaction effects of the phosphodiesterase 5 inhibitors: Focus on ?-blocker interactions. Am J Cardiol 2005;96(12 SUPPL. 2):
Kloner R, Padma-Nathan H. Erectile dysfunction in patients with coronary artery disease. [Review] [40 refs]. Int J Impot Res. 2005;17(3):209-215. [pmid: 15729374].
Koppiker N, Boolell M, Price D. Recent advances in the treatment of erectile dysfunction in patients with diabetes mellitus. [Review] [111 refs]. Endocr Pract. 2003;9(1):52-63. [pmid: 12917094].
Korenman SG. New insights into erectile dysfunction: A practical approach. Am J Med. 1998;105(2):135-144. [pmid: 9727821].
Kuan J, Brock G. Selective phosphodiesterase type 5 inhibition using tadalafil for the treatment of erectile dysfunction. Expert Opin Investig Drugs. 2002;11(11):1605-1613.
Kubin M, Wagner G, Fugl-Meyer AR. Epidemiology of erectile dysfunction. Int J Impot Res. 2003;15(1):63-71. [pmid: 12605242].
Kulkarni SK, Patil CS. Phosphodiesterase 5 enzyme and its inhibitors: Update on pharmacological and therapeutical aspects. Methods & Findings in Experimental & Clinical Pharmacology. 2004;26(10):789-799. [pmid: 15672122].
Kuritzky L. Noninvasive management of lower urinary tract symptoms and sexual dysfunction associated with benign prostatic hyperplasia in the primary care setting. Compr Ther. 2005;31(3):194-208. [pmid: 16110128].
Kuthe A. Phosphodiesterase 5 inhibitors in male sexual dysfunction. Curr Opin Urol. 2003;13(5):405-410. [pmid: 12917517].
Labbate L A, Croft H A, Oleshansky M A. Antidepressant-related erectile dysfunction: management via avoidance, switching antidepressants, antidotes, and adaptation. [Review][82 refs]. Hillside J Clin Psychiatry 2003;64Suppl-9.
Lau DH, Mumtaz FH, Thompson CS, et al. Erectile dysfunction: A need for greater awareness. Journal of the Royal Society for the Promotion of Health. 2004;124(5):214-216. [pmid: 15493779].
Lauterbach EC. The neuropsychiatry of Parkinson's disease and related disorders. Psychiatr Clin North Am. 2004;27(4):801-825. [pmid: 15550293].
Lazarou S, Morgentaler A. Hypogonadism in the man with erectile dysfunction: what to look for and when to treat. [Review] [40 refs]. Curr Urol Rep. 2005;6(6):476-481. [pmid: 16238923].
Ledda A. Erectile dysfunction: intracavernous treatment. [Review] [12 refs]. Current Medical Research & Opinion. 2000;16(Suppl 1):s59-s62. [pmid: 11329824].
Lee-Chiong TL. Parasomnias and other sleep-related movement disorders. Primary Care; Clinics in Office Practice. 2005;32(2):415-434.
Leiblum Sandra R, Rosen Raymond C. Couples therapy for erectile disorders: Conceptual and clinical considerations. J Sex Marital Ther. 1991;17(2):147-159. [pmid: 1920470].
Lepor H. Radical prostatectomy: Status and opportunities for improving outcomes. Cancer Invest. 2004;22(3):435-444. [pmid: 15493364].
Levine L A. Diagnosis and treatment of erectile dysfunction. [Review][32 refs]. Am J Med 2000;109Suppl-12S.
Levine LA. Erectile dysfunction following treatment of prostate cancer: New insights and therapeutic options. The Journal of Mens Health & Gender. 2004;1(4):328-333.
Levine Laurence AE. Erectile dysfunction following treatment of prostate cancer: new insights and therapeutic options. [References]. Journal of Men's Health & Gender. 2004;1(4):328-333.
Levy A, Crowley T, Gingell C. Non-surgical management of erectile dysfunction. [Review] [103 refs]. Clin Endocrinol (Oxf). 2000;52(3):253-260. [pmid: 10718821].
Lewis JM, Osbourne ALM, O'Leary MP. Erectile dysfunction. J Med Liban. 2004;52(4):213-216. [pmid: 16432984].
Lewis J, Helfrick B, Marzucco J. Clinical conversations: intraurethral alprostadil (MUSE). Interview by Patricia Bates. Urol Nurs. 1997;17(4):159-161. [pmid: 9451246].
Lewis R. Review of intraurethral suppositories and iontophoresis therapy for erectile dysfunction. [Review][18 refs]. Int J Impot Res 2000;12Suppl-90.
Linsenmeyer TA. Evaluation and treatment of erectile dysfunction following spinal cord injury: a review. [Review] [65 refs]. J Am Paraplegia Soc. 1991;14(2):43-51. [pmid: 2051156].
Lischer GH, Nehra A. Therapies for neurologic erectile dysfunction. Expert Review of Neurotherapeutics. 2003;3(5):641-648. [pmid: 19810964].
Lording DW. Erectile dysfunction: Update on oral therapies. Med Today. 2003;4(5):58-66.
Lue TF. Topical and oral agents for erectile dysfunction. J Formos Med Assoc. 1999;98(4):233-241. [pmid: 10389366].
Lue TF, Lee KL. Pharmacotherapy for erectile dysfunction. [Review] [45 refs]. Chin Med J. 2000;113(4):291-298. [pmid: 11775221].
Maan Z, Arya M, Patel HRH. Priapism - A review of the medical management. Expert Opin Pharmacother. 2003;4(12):2271-2277. [pmid: 14640926].
Magoha GA. Management of male erectile dysfunction: a review.[see comment]. [Review] [55 refs]. East Afr Med J. 1998;75(11):623-627. [pmid: 10065171].
Mak KY. Management of sexual dysfunction in primary care. Hong Kong Practitioner. 2004;26(12):527-532.
Marshall VL, Grosset DG. GPI-1485 Guilford. Curr Opin Investig Drugs. 2004;5(1):107-112.
Martin WJ, MacIntyre DE. Melanocortin receptors and erectile function. Eur Urol. 2004;45(6):706-713. [pmid: 15149741].
Martin-Morales A, Rosen RC. Effective treatment of erectile dysfunction with vardenafil. Med Actual. 2003;39(1):51-59.
Masson P, Lambert SM, Brown M, et al. PDE-5 inhibitors: current status and future trends. [Review] [80 refs]. Urol Clin North Am. 2005;32(4):511-525. [pmid: 16291042].
Matfin G. New treatments for erectile dysfunction. Sexuality, Reproduction & Menopause. 2003;1(1):40-45.
Matfin G, Jawa A, Fonseca VA. Erectile dysfunction: Interrelationship with the metabolic syndrome. Curr Diab Rep. 2005;5(1):64-69. [pmid: 15663920].
McCullough AR. An Update on the PDE-5 Inhibitors (PDE-5i). J Androl. 2003;24(6 SUPPL.):S52-S58. [pmid: 14581496].
McCullough AR. Prevention and management of erectile dysfunction following radical prostatectomy. [Review] [67 refs]. Urol Clin North Am. 2001;28(3):613-627. [pmid: 11590817].
McKay D. Nutrients and botanicals for erectile dysfunction: examining the evidence. Altern Med Rev. 2004;9(1):4-16. [pmid: 15005641].
McLeod AL, McKenna CJ, Northridge DB. Myocardial infarction following the combined recreational use of Viagra and cannabis. Clin Cardiol. 2002;25(3):133-134. [pmid: 11890373].
McMahon CG. New treatment options for erectile dysfunction. [Review] [10 refs]. Aust Fam Physician. 1999;28(8):783-787. [pmid: 10495526].
McMahon CG. Current concepts in the management of post-radical prostatectomy impotence. Curr Opin Urol. 1998;8(6):535-540. [pmid: 17039073].
Mealy NE. Apomorphine hydrochloride, new formulations. Drugs of the Future. 2004;29(6):627-628.
Meuleman EJH. Review of tadalafil in the treatment of erectile dysfunction. Expert Opin Pharmacother. 2003;4(11):2049-2056. [pmid: 14596658].
Meuleman EJH, Hedlund Pryor, Nehra Althof, et al. Prevalence of erectile dysfunction: Need for treatment?. Int J Impot Res. 2002;14(SUPPL. 1):S22-S28. [pmid: 11850731].
Meyer JJ. Impotence. Assessment in the private-practice office. Postgrad Med. 1994;84(2):87-91. [pmid: 3399472].
Michel MC. Lower Urinary Tract Disorders - Ray Fuller Symposium Physiology, Pharmacology and Therapeutic Approaches 6–7 July 2002, San Francisco, CA, USA. IDrugs. 2002;5(8):792-796.
Michelakis E, Tymchak W, Archer S. Sildenafil: from the bench to the bedside. [Review] [10 refs]. CMAJ Canadian Medical Association Journal. 2000;163(9):1171-1175. [pmid: 11079066].
Mikhail N. Management of erectile dysfunction by the primary care physician. Cleve Clin J Med. 2005;72(4):293-311. [pmid: 15850242].
Minhas S, Kalsi JS, Ralph DJ. Cialis (tadalafil): a new treatment for erectile dysfunction. [Review] [13 refs]. Hospital Medicine (London). 2003;64(10):589-592.
Mitka M. Researchers Seek New Uses for Sildenafil. J Am Med Assoc. 2003;289(21):2784-2786.
Mobley DF, Baum N. Medical management of benign prostatic hyperplasia in older adults. Geriatrics and Aging. 2004;7(6):23-28.
Mohan R, Bhugra D. Literature update: A critical review. Sexual & Relationship Therapy. 2005;20(1):115-122.
Mohr David C, Beutler Larry E. Erectile dysfunction: A review of diagnostic and treatment procedures. Clin Psychol Rev. 1990;10(1):123-150.
Monga M, Bernie J, Rajasekaran M. Male infertility and erectile dysfunction in spinal cord injury: a review. [Review] [86 refs]. Archives of Physical Medicine & Rehabilitation. 1999;80(10):1331-1339. [pmid: 10527097].
Montague DK, Angermeier KW. Current status of penile prosthesis implantation. [Review] [55 refs]. Curr Urol Rep. 2000;1(4):291-296. [pmid: 12084306].
Montorsi F. Tolerability and safety of apomorphine SL (Ixense (TM)). [Review][9 refs]. Int J Impot Res 2003;15Suppl-9.
Montorsi F. Oral pharmacotherapy for erectile dysfunction: A personal view of experiences with three different drugs. The Journal of Mens Health & Gender. 2004;1(1):29-31.
Montorsi F. The role of apomorphine SL in the treatment of erectile dysfunction. European Urology Supplements. 2002;1(3):4-11.
Montorsi F, Oettel M. Testosterone and sleep-related erections: an overview*. [Review] [142 refs]. Br J Sex Med. 2005;2(6):771-784.
Montorsi F, Corbin J, Phillips S. Review of phosphodiesterases in the urogenital system: New directions for therapeutic intervention. Br J Sex Med. 2004;1(3):322-336.
Montorsi F, Guazzoni G, Rigatti P, et al. Pharmacological management of erectile dysfunction. [Review] [59 refs]. Drugs. 1995;50(3):465-479. [pmid: 8521769].
Montorsi F, Kuritzky L, Sadovsky R, et al. Frequently asked questions about tadalafil for treating men with erectile dysfunction. The Journal of Mens Health & Gender. 2005;2(1):141-157.
Montorsi F, Padma-Nathan H, Glina S. Erectile function and assessments of erection hardness correlate positively with measures of emotional well-being, sexual satisfaction, and treatment satisfaction in men with erectile dysfunction treated with sildenafil citrate (Viagra). [Review] [45 refs]. Urology. 2006;68(3 Suppl):26-37. [pmid: 17011373].
Montorsi F, Salonia A, Deho' F, et al. Pharmacological management of erectile dysfunction. [Review] [52 refs]. BJU Int. 2003;91(5):446-454. [pmid: 12603396].
Montorsi F, Salonia A, Zanoni M, et al. Counselling the patient with prostate cancer about treatment-related erectile dysfunction. Curr Opin Urol. 2001;11(6):611-617. [pmid: 11734698].
Montouris G, Morris GL. Reproductive and sexual dysfunction in men with epilepsy. Epilepsy Behav. 2005;7(SUPPL. 2):S7-S14. [pmid: 16243004].
Moore CR, Wang R. Pathophysiology and treatment of diabetic erectile dysfunction. [Review] [84 refs]. Asian J Androl. 2006;8(6):675-684. [pmid: 16892168].
Morales A. Yohimbine in erectile dysfunction: would an orphan drug ever be properly assessed?. [Review] [43 refs]. World J Urol. 2001;19(4):251-255. [pmid: 11550783].
Morales A. Erectile dysfunction: An overview. Clin Geriatr Med. 2003;19(3):529-538. [pmid: 14567005].
Morales A. Testosterone replacement: when is there a role?. [Review] [39 refs]. Int J Impot Res. 2000;12(Suppl 4):S112-S118. [pmid: 11035397].
Morales A, Heaton JP. Hormonal erectile dysfunction. Evaluation and management. Urol Clin North Am. 2001;28(2):279-288. [pmid: 11402581].
Morales A, Heaton JP. Hypogonadism and erectile dysfunction: pathophysiological observations and therapeutic outcomes. [Review] [24 refs]. BJU Int. 2003;92(9):896-899. [pmid: 14632842].
Morales A, Porst Wyllie. Developmental status of topical therapies for erectile and ejaculatory dysfunction. Int J Impot Res. 2000;12(SUPPL. 4):S80-S85. [pmid: 11035392].
Moreland RB, Nakane M, Hsieh G, et al. Prospectives for pharmacotherapy of male erectile dysfunction. Current Opinion in Central & Peripheral Nervous System Investigational Drugs. 2000;2(3):283-302.
Morelli A, Vignozzi L, Filippi S, et al. Erectile dysfunction: Molecular biology, pathophysiology and pharmacological treatment. Minerva Urol Nefrol. 2005;57(2):85-90. [pmid: 15951732].
Morley JE, Perry HM. Androgen treatment of male hypogonadism in older males. [Review] [72 refs]. Journal of Steroid Biochemistry & Molecular Biology. 2003;85(25):367-373. [pmid: 12943724].
Moyad MA. Promoting general health during androgen deprivation therapy (ADT): A rapid 10-step review for your patients. Urol Oncol. 2005;23(1):56-64. [pmid: 15885584].
Mulcahy JJ. Erectile function after radical prostatectomy. [Review] [27 refs]. Semin Urol Oncol. 2000;18(1):71-75. [pmid: 10719936].
Mulhall JP. Understanding erectile dysfunction medication preference studies. [Review] [42 refs]. Curr Opin Urol. 2004;14(6):367-373. [pmid: 15626881].
Mulhall JP. Current concepts in erectile dysfunction. Am J Manag Care. 2000;6(12:Suppl):Suppl-31.
Mulhall JP. Intracavernosal injection therapy: a practical guide. Tech Urol. 1997;3(3):129-134. [pmid: 9422443].
Mulhall JP, Montorsi F. Evaluating preference trials of oral phosphodiesterase 5 inhibitors for erectile dysfunction. Eur Urol. 2006;49(1):30-37. [pmid: 16263207].
Muller SC, el-Damanhoury H, Ruth J, et al. Hypertension and impotence. Eur Urol. 1991;19(1):29-34. [pmid: 2007414].
Mulligan T, Katz PG. Urologic considerations in geriatric erectile failure. [Review] [55 refs]. Clin Geriatr Med. 1991;7(1):73-84. [pmid: 2004292].
Mulligan T, Teitelman J. Geriatric sexual dysfunction. [Review] [15 refs]. Va Med Q. 1991;118(2):97-99. [pmid: 2039781].
Mulligan T, Reddy S, Gulur PV, et al. Disorders of male sexual function. Clin Geriatr Med. 2003;19(3):473-481. [pmid: 14567002].
Murray FT, Geisser ME, Cohen MS, et al. Evaluation and treatment of sexual dysfunction in men with diabetes mellitus. [Review] [21 refs]. J Fla Med Assoc. 1991;78(11):757-761. [pmid: 1765757].
Nehra A. Selecting therapy for maintaining sexual function in patients with benign prostatic hyperplasia. BJU Int. 2005;96(3):237-243. [pmid: 16042709].
Nehra A. Treatment of endocrinologic male sexual dysfunction. [Review] [22 refs]. Mayo Clin Proc. 2000;75(Suppl):S40-S45. [pmid: 10959215].
Nehra A, Kulaksizoglu H. Combination therapy for erectile dysfunction: where we are and what's in the future. [Review] [30 refs]. Curr Urol Rep. 2002;3(6):467-470. [pmid: 12425869].
Nehra A, Moreland RB. Neurologic erectile dysfunction. Urol Clin North Am. 2001;28(2):289-308. [pmid: 11402582].
Nehra A, Steers WD, Althof SE, et al. Third international conference on the management of erectile dysfunction: Linking pathophysiology and therapeutic response. Br J Urol. 2003;170(2 II):S3-S5.
Noss MB, Christ GJ, Melman A. Sildenafil: A new oral therapy for erectile dysfunction. Med Actual. 1999;35(3):211-217.
Nurnberg HG. Managing treatment-emergent sexual dysfunction associated with serotonergic antidepressants: before and after sildenafil. J Psychiatr Pract. 2001;7(2):92-108. [pmid: 15990510].
Nutt D, Johnson FN. Potential applications of venlafaxine. Reviews in Contemporary Pharmacotherapy. 1998;9(5):321-331.
O'Farrell Timothy J. Sexual functioning of male alcoholics. Collins, R 1990;Lorraine(Ed):Kenneth-271.
O'Keefe M, Hunt DK. Assessment and treatment of impotence. [Review] [104 refs]. Med Clin North Am. 1995;79(2):415-434. [pmid: 7877399].
O'Leary M. Erectile dysfunction.[update in Clin Evid. 2002 Dec;(8):872–80; PMID: 15259177]. [Review][19 refs]. Clin Evid 2002;(7):796–803.
Olin JW, Jang J, Jaff MR, et al. The top 12 advances in vascular medicine. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2004;11(SUPPL. 2):II21-II31.
Opsomer RJ. Treatment of Erectile Dysfunction. Acta Clin Belg. 2002;57(5):272-276. [pmid: 12534135].
Owens J. David Brown: Proteomicsin drug discovery. Drug Discovery Today Targets. 2003;2(4):134-137.
Padma-Nathan H. Efficacy and tolerability of tadalafil, a novel phosphodiesterase 5 inhibitor, in treatment of erectile dysfunction. [Review] [20 refs]. Am J Cardiol. 2003;92(9A):19M-25M.
Padma-Nathan H. A new era in the treatment of erectile dysfunction. Am J Cardiol. 1999;84(5B):18N-23N. [pmid: 10404845].
Padma-Nathan H. Sildenafil citrate (Viagra(TM)): An update. Mol Urol. 1999;3(2):127-134. [pmid: 10851314].
Padma-Nathan H. Sildenafil citrate (Viagra) treatment for erectile dysfunction: An updated profile of response and effectiveness. Int J Impot Res. 2006;18(5):423-431. [pmid: 16810179].
Padma-Nathan H, Giuliano F. Oral drug therapy for erectile dysfunction. Urol Clin North Am. 2001;28(2):321-334. [pmid: 11402584].
Padma-Nathan Harin, Christ George, Adaikan Ganesan, et al. Pharmacotherapy for Erectile Dysfunction. [References]. Br J Sex Med. 2004;1(2):128-140.
Pedersen Beth L, Mohl Bo. Behind every penis is a man. Nord Sexol. 1991;9(4):226-231.
Penedo FJ, Dahn JR. Prostate cancer and QOL: Impact of treatment, disease burden and psychosocial interventions. Expert Review of Pharmacoeconomics & Outcomes Research. 2004;4(5):525-535. [pmid: 19807546].
Peterson Frederick L J. The assessment and treatment of erection dysfunction. Vandecreek, Leon (Ed); Jackson, Thomas L (Ed) 2000;(2000):18–71.
Pomerol JM, Rabasseda X. Tadalafil, a further innovation in the treatment of sexual dysfunction. [Review] [39 refs]. Med Actual. 2003;39(2):103-113.
Porst H. The rationale for prostaglandin E1 in erectile failure: a survey of worldwide experience. [Review] [219 refs]. Br J Urol. 1996;155(3):802-815.
Porst H. Restoring a normal sexual response: The ultimate goal of erectile dysfunction therapy. European Urology Supplements. 2002;1(8):19-24.
Porst H, Pryor Heaton, Nehra. Current perspectives on intracavernosal pharmacotherapy for erectile dysfunction. Int J Impot Res. 2000;12(SUPPL. 4):S91-S100. [pmid: 11035394].
Potts Annie, Grace Victoria, Gavey Nicola, et al. “Viagra stories”: Challenging ‘erectile dysfunction’. [References]. Soc Sci Med. 2004;59(3):489-499. [pmid: 15144760].
Pryor JL, Redmon B, Wilson Wyllie, et al. New therapies and delivery mechanisms for treatment of erectile dysfunction. Int J Impot Res. 2000;12(SUPPL. 4):S158-S162. [pmid: 11035406].
Pryor JP. Safety of sildenafil. [Review] [25 refs]. Curr Opin Urol. 2000;10(6):613-615. [pmid: 11148735].
Pryor JP. Pharmacotherapy of erectile dysfunction. Sexual & Relationship Therapy. 2002;17(4):389-400.
Raeburn JN. Erectile dysfunction. Cme Bulletin Endocrinology & Diabetes. 2000;3(2):52-55.
Ramos AS, Samso JV. Specific aspects of erectile dysfunction in spinal cord injury. [Review] [22 refs]. Int J Impot Res. 2004;16(Suppl 2):S42-S45. [pmid: 15496857].
Ramsay LE, Yeo WW, Jackson PR. Thiazide diuretics: first-line therapy for hypertension. [Review]. Journal of Hypertension - Supplement. 1992;10(3):S29-S32.
Reckelhoff JF, Yanes LL, Iliescu R, et al. Testosterone supplementation in aging men and women: Possible impact on cardiovascular-renal disease. American Journal of Physiology - Renal Physiology. 2005;289(5 585):F941-F948. [pmid: 16210452].
Reffelmann T, Kloner RA. Pharmacotherapy of erectile dysfunction: Focus on cardiovascular safety. Expert Opin Drug Saf. 2005;4(3):531-540. [pmid: 15934858].
Reffelmann T, Kloner RA. Sexual function in hypertensive patients receiving treatment. Vascular Health & Risk Management. 2006;2(4):447-455. [pmid: 17323599].
Reffelmann T, Kloner RA. Cardiovascular effects of phosphodiesterase 5 inhibitors. Curr Pharm Des. 2006;12(27):3485-3494. [pmid: 17017941].
Reisner GS. Impotence. Aust Fam Physician. 1993;22(8):1393-1397. [pmid: 8379880].
Renshaw Domeena C. Sexuality. Sadavoy, Joel (Ed); Lazarus, Lawrence W (Ed); Jarvik, Lissy F (Ed) 1991;(1991):770
Rhoden EL, Morgentaler A. Erectile Dysfunction. J Long Term Eff Med Implants. 2003;13(6):519-528. [pmid: 15056069].
Rhoden Ernani, Morgentaler Abraham Luis, et al. Risks of Testosterone-Replacement Therapy and Recommendations for Monitoring. [References]. N Engl J Med. 2004;350(5):482-492. [pmid: 14749457].
Riley AJ. Yohimbine in the treatment of erectile disorder. [Review] [38 refs]. Br J Clin Pract. 1994;48(3):133-136. [pmid: 8031688].
Riley Alan J, Peet Malcolm, Wilson Catherine. Sexual pharmacology. Refuat Hapeh Vehashinayim 1993;xii, 235 pp. New York, NY, US235
Rodriguez J J, Al Dashti R, Schwarz E R. Linking erectile dysfunction and coronary artery disease. Int J Impot Res 2005;17(SUPPL. S1):
Roehrborn CG, McNicholas T. The Management of Prostatic Obstruction: How to Determine the Best Options?. European Urology Supplements. 2003;2(8):13-19.
Rogers ZR. Priapism in sickle cell disease. Hematology - Oncology Clinics of North America. 2005;19(5):917-928.
Rosen RC, McKenna KE. PDE-5 inhibition and sexual response: pharmacological mechanisms and clinical outcomes. [Review] [165 refs]. Annu Rev Sex Res. 2002;13:36-88. [pmid: 12836729].
Rosen RC, Giuliano F, Carson CC. Sexual dysfunction and lower urinary tract symptoms (LUTS) associated with benign prostatic hyperplasia (BPH). Eur Urol. 2005;47(6):824-837. [pmid: 15925080].
Rosenberg KP. Sildenafil. J Sex Marital Ther. 1999;25(4):271-279. [pmid: 10546165].
Rotella DP. Tadalafil Lilly ICOS. [Review] [38 refs]. Curr Opin Investig Drugs. 2003;4(1):60-65.
Rotella D P. Phosphodiesterase 5 inhibitors: current status and potential applications. [Review][55 refs]. Nat Rev Genet 2002;Drug(9):674–682.
Roy JB. Advances in the management of impotence. [Review] [19 refs]. J Okla State Med Assoc. 1998;91(1):14-16. [pmid: 9503755].
rruda-Olson AM, Pellikka PA. Appropriate use of exercise testing prior to administration of drugs for treatment of erectile dysfunction. [Review] [47 refs]. Herz. 2003;28(4):291-297. [pmid: 12825144].
Rushton David N. Sexual and sphincter dysfunction. Bradley, Walter G (Ed); Daroff, Robert B (Ed); Fenichel, Gerald M (Ed); Marsden, C 1991;David(Ed):1–391.
Russell ST, Khandheria BK, Nehra A. Erectile dysfunction and cardiovascular disease. Mayo Clin Proc. 2004;79(6):782-794. [pmid: 15182094].
Sadovsky R, Dhindsa S, Margo K. Testosterone deficiency: Which patients should you screen and treat?. J Fam Pract. 2007;56(5):S1-S21. [pmid: 17475159].
Sadovsky R, Miller T, Moskowitz M, et al. Three-year update of sildenafil citrate (Viagra) efficacy and safety. Int J Clin Pract. 2001;55(2):115-128. [pmid: 11321851].
de Saenz, Tejada I, Angulo J, et al. Pathophysiology of erectile dysfunction. Br J Sex Med. 2005;2(1):26-39.
Sandel M, Elizabeth. Traumatic brain injury. Sipski, Marca L (Ed); Alexander, Craig J (Ed) 1997;(1997):651
Schover Leslie R. Erectile failure and chronic illness. Rosen, Raymond C (Ed); Leiblum, Sandra Risa (Ed) 1992;(1992):378
Schubert M, Jockenhovel F. Late-onset hypogonadism in the aging male (LOH): definition, diagnostic and clinical aspects. J Endocrinol Invest. 2005;28(3 Suppl):23-27. [pmid: 16042356].
Schubert M, Zitzmann M, Yassin A. Intramuscular testosterone undecanoate for the treatment of male hypogonadism-review of recent data. The Journal of Mens Health & Gender. 2006;3(4):356-362.
Schulman CC. Lower urinary tract symptoms/benign prostatic hyperplasia: minimizing morbidity caused by treatment. [Review] [45 refs]. Urology. 2003;62(3:Suppl 1):Suppl-33.
Schultheiss D. Regenerative medicine in andrology: Tissue engineering and gene therapy as potential treatment options for penile deformations and erectile dysfunction. Eur Urol. 2004;46(2):162-169. [pmid: 15245808].
Seftel A. Testosterone replacement therapy for male hypogonadism: Part III. Pharmacologic and clinical profiles, monitoring, safety issues, and potential future agents. Int J Impot Res. 2007;19(1):2-24. [pmid: 16193074].
Seftel AD. Phosphodiesterase type 5 inhibitors: Molecular pharmacology and interactions with other phosphodiesterases. Curr Pharm Des. 2005;11(31):4047-4058. [pmid: 16378510].
Seftel AD. Tadalafil: A long-acting PDE5 inhibitor for the management of erectile dysfunction. Therapy. 2004;1(2):185-196.
Seftel AD, Farber J, Fletcher J, et al. A three-part study to investigate the incidence and potential etiologies of tadalafil-associated back pain or myalgia. Int J Impot Res. 2005;17(5):455-461. [pmid: 16034469].
Seftel AD, Mohammed MA, Althof SE. Erectile dysfunction: Etiology, evaluation, and treatment options. Med Clin North Am. 2004;88(2):387-416. [pmid: 15049584].
Segraves RT. New treatment for erectile dysfunction. [Review] [38 refs]. Curr Psychiatry Rep. 2000;2(3):206-210. [pmid: 11122957].
Segraves RT. Treatment of erectile dysfunction: A psychiatric perspective. Primary Psychiatry. 2004;11(12):58-68.
Segraves RT, Segraves KB. Pharmacotherapy for sexual disorders: Advantages and pitfalls. Sexual & Marital Therapy. 1998;13(3):295-309.
Segraves R, Taylor Althof, Stanley. Psychotherapy and pharmacotherapy of sexual dysfunctions. Nathan, Peter E (Ed); Gorman, Jack M (Ed) 1998;(1998):594
Senn S. Individual response to treatment: Is it a valid assumption?. Br Med J. 2004;329(7472):966-968. [pmid: 15499115].
Shabsigh R. Therapy of ED: PDE-5 inhibitors. Endocrine. 2004;23(23):135-141. [pmid: 15146092].
Shabsigh R, Anastasiadis A G. Erectile Dysfunction. Annu Rev Med 2003;54(pp 153–168):-168.
Shabsigh R, Rajfer J, Aversa A, et al. The evolving role of testosterone in the treatment of erectile dysfunction. Int J Clin Pract. 2006;60(9):1087-1092. [pmid: 16939550].
Sharlip I. Diagnosis and treatment of premature ejaculation: The physician's perspective. Br J Sex Med. 2005;2(SUPPL. 2):103-109.
Sharlip ID. Does natural erectile function improve following intracavernous injections of vasoactive drugs?. [Review] [12 refs]. Int J Impot Res. 1997;9(4):193-196. [pmid: 9442416].
Sharlip ID. Evaluation and nonsurgical management of erectile dysfunction. Urol Clin North Am. 1998;25(4):647-659. [pmid: 10026772].
Shinlapawittayatorn K, Chattipakorn S, Chattipakorn N. Effect of sildenafil citrate on the cardiovascular system. Brazilian Journal of Medical & Biological Research. 2005;38(9):1303-1311. [pmid: 16138212].
Simonsen U. Interactions between drugs for erectile dysfunction and drugs for cardiovascular disease. [Review] [121 refs]. Int J Impot Res. 2002;14(3):178-188. [pmid: 12058245].
Singh JC, Devasia A, Gnanaraj L, et al. Erectile dysfunction. [Review] [21 refs]. Natl Med J India. 2005;18(3):139-143. [pmid: 16130616].
Smith David M, Levitte Susan S. Association of fluoxetine and return of sexual potency in three elderly men. Hillside J Clin Psychiatry. 1993;54(8):317-319.
Snow KJ. Erectile dysfunction: A review and update. Hosp Formul. 2004;39(5):261-268.
Solomon H, DeBusk RF, Jackson G. Erectile dysfunction: The need to be evaluated, the right to be treated. Am Heart J. 2005;150(4):620-626. [pmid: 16209956].
Sommer F, Engelmann U. Future options for combination therapy in the management of erectile dysfunction in older men. Drugs Aging. 2004;21(9):555-564. [pmid: 15260511].
Sperling H, Lummen G, Schneider T, et al. [New treatment options for erectile dysfunction. Pharmacologic and nonpharmacologic options]. Herz. 2003;28(4):314-324. [pmid: 12825147].
Stahl Stephen M. How psychiatrists can build new therapies for impotence. Hillside J Clin Psychiatry. 1998;59(2):47-48.
Steers WD. Viability and safety of combination drug therapies for erectile dysfunction. [Review] [20 refs]. Br J Urol. 2003;170(2:Pt 2):t-3.
Steers WD, Rosen R, Andersson KE, et al. Viability and safety of combination drug therapies for erectile dysfunction. Br J Urol. 2003;170(2 II):S20-S23.
Stenager Egon, Stenager Elsebeth, Nylev Jensen, et al. Sexual problems in multiple sclerosis. Int J Adolesc Med Health. 1994;7(2):95-105. [pmid: 22912150].
Stimmel GL, Gutierrez MA. Pharmacologic treatment strategies for sexual dysfunction in patients with epilepsy and depression. CNS Spectr. 2006;11(SUPPL. 9):31-37. [pmid: 16871136].
Sui Z. Phosphodiesterase-5 inhibitors for male erectile dysfunction. Expert Opinion on Therapeutic Patents. 2003;13(9):1373-1388.
Susman E. American Urological Association - 97th Annual Meeting: Progress in sexual dysfunction: 25–30 May 2002, Orlando, FL, USA. IDrugs. 2002;5(7):666-669. [pmid: 14686346].
Swerdloff RS, Wang C. Androgens and the ageing male. Best Practice & Research Clinical Endocrinology & Metabolism. 2004;18(3):349-362. [pmid: 15261842].
Telang DJ, Farah RN. Management of impotence after treatment of carcinoma of the prostate. [Review] [16 refs]. Henry Ford Hosp Med J. 1992;40(12):111-113. [pmid: 1428960].
Teloken C. Management of erectile dysfunction secondary to treatment for localized prostate cancer. [Review] [42 refs]. Cancer Control. 2001;8(6):540-545. [pmid: 11807424].
Temel Y, Hafizi S, Beuls E, et al. The supraspinal network in the control of erection. Expert Opin Ther Targets. 2005;9(5):941-954. [pmid: 16185150].
Tenover JS. Prevalence and management of mild hypogonadism: Introduction. Int J Impot Res. 2003;15(SUPPL. 4):S1-S2. [pmid: 12934043].
Thachil A, Bhugra D. Literature update: A critical review. Sexual & Relationship Therapy. 2005;20(4):457-464.
Thomas JA. Pharmacological aspects of erectile dysfunction. Jpn J Pharmacol. 2002;89(2):101-112. [pmid: 12120751].
Tilton Margaret C. Diabetes and amputation. Sipski, Marca L (Ed); Alexander, Craig J (Ed) 1997;(1997):651
Toda N, Ayajiki K, Okamura T. Nitric oxide and penile erectile function. Pharmacol Ther. 2005;106(2):233-266. [pmid: 15866322].
Toone Brian K. Sexual dysfunction. Keshavan, Matcheri S (Ed); Kennedy, John S (Ed) 1992;(1992):339
Tran D, Howes LG. Cardiovascular safety of sildenafil. [Review] [38 refs]. Drug Saf. 2003;26(7):453-460. [pmid: 12735784].
Uckert S, Stief CG, Jonas U. Current and future trends in the oral pharmacotherapy of male erectile dysfunction. Expert Opin Investig Drugs. 2003;12(9):1521-1533.
Utida C, Truzzi JC, Bruschini H, et al. Male infertility in spinal cord trauma. [Review] [64 refs]. International Braz J Urol. 2005;31(4):375-383. [pmid: 16137408].
Vale J. Erectile dysfunction following radical therapy for prostate cancer. Radiotherapy & Oncology. 2000;57(3):301-305. [pmid: 11104890].
Vardi Y, Gruenwald I. Cardiovascular effects of oral pharmacotherapy in erectile dysfunction. Current Medical Research & Opinion, Supplement. 1999;16(1):s42-s47.
Vickers MA, Satyanarayana R. Phosphodiesterase type 5 inhibitors for the treatment of erectile dysfunction in patients with diabetes mellitus. Int J Impot Res. 2002;14(6):466-471. [pmid: 12494279].
Vinik A, Richardson D. Erectile dysfunction in diabetes. Diabetes Reviews. 1998;6(1):16-33.
Vinik AI, Mehrabyan A. Diabetic neuropathies. Med Clin North Am. 2004;88(4):947-999. [pmid: 15308387].
Vitezic D, Pelcic JM. Erectile dysfunction: oral pharmacotherapy options. [Review] [72 refs]. International Journal of Clinical Pharmacology & Therapeutics. 2002;40(9):393-403. [pmid: 12358156].
Wakley Gill. The management of impotence in general practice. Lincoln, Rosemarie (Ed) 1992;(1992):193
Waldinger Marcel D. Use of psychoactive agents in the treatment of sexual dysfunction. CNS Drugs. 1996;6(3):204-216.
Wespes E. Intracavernous injection as an option for aging men with erectile dysfunction. [Review] [21 refs]. Aging Male. 2002;5(3):177-180. [pmid: 12471778].
Wessells H, Blevins JE, Vanderah TW. Melanocortinergic control of penile erection. Peptides. 2005;26(10):1972-1977. [pmid: 15992962].
wey RB. Autonomic dysfunction in Parkinson's disease. Neurol Clin. 2004;22(3 SUPPL.):S127-S139. [pmid: 15501361].
Wierman ME, Cassel CK. Erectile dysfunction: A multifaceted disorder. Hospital Practice (Office Edition). 1998;33(10):65-90.
Williams G. Erectile dysfunction-advances. [Review] [4 refs]. Br J Gen Pract. 1991;235(1499):114-118.
Witherington R. Vacuum devices for the impotent. [Review] [11 refs]. J Sex Marital Ther. 1991;17(2):69-80. [pmid: 1920471].
Wright PJ. Comparison of phosphodiesterase type 5 (PDE5) inhibitors. [Review] [59 refs]. Int J Clin Pract. 2006;60(8):967-975. [pmid: 16780568].
Young JM. Vardenafil. Expert Opin Investig Drugs. 2002;11(10):1487-1496.
Zonszein J. Diagnosis and management of endocrine disorders of erectile dysfunction. Urol Clin North Am. 1995;22(4):789-802. [pmid: 7483129].

## Guideline

Anonymous. American association of clinical endocrinologists medical guidelines for clinical practice for the evaluation and treatment of male sexual dysfunction: A couple's problem - 2003 update. Endocr Pract 2003;9(1):77–94.
Conway AJ, Handelsman DJ, Lording DW, et al. Use, misuse and abuse of androgens. The Endocrine Society of Australia consensus guidelines for androgen prescribing.[erratum appears in Med J Aust 2000 Apr 3;172(7):334]. Med J Aust. 2000;172(5):220-224. [pmid: 10776394].
Hatzichristou DG, Bertero EB, Goldstein I. Decision making in the evaluation of impotence: The patient profile- oriented algorithm. Sexuality & Disability. 1994;12(1):29-37.
Hatzichristou D, Rosen RC, Broderick G, et al. Clinical evaluation and management strategy for sexual dysfunction in men and women. Br J Sex Med. 2004;1(1):49-56.
Hirsch M, Donatucci C, Glina S, et al. Standards for clinical trials in male sexual dysfunction: Erectile dysfunction and rapid ejaculation. Br J Sex Med. 2004;1(1):87-91.
Jackson G, Betteridge J, Dean J, et al. A systematic approach to erectile dysfunction in the cardiovascular patient: A consensus treatment - Update 2002. Int J Clin Pract. 2002;56(9):663-671. [pmid: 12469980].
Lewis RW, Fugl-Meyer KS, Bosch R, et al. Epidemiology/risk factors of sexual dysfunction. Br J Sex Med. 2004;1(1):35-39.
Lue TF, Giuliano F, Montorsi F, et al. Summary on the recommendations on sexual dysfunctions in men. Br J Sex Med. 2004;1(1):6-23.
Montague DK, Barada JH, Belker AM, et al. Clinical guidelines panel on erectile dysfunction: summary report on the treatment of organic erectile dysfunction. The American Urological Association. Br J Urol. 1996;156(6):2007-2011.
Perlis Roy H, Fava Maurizio, Nierenberg Andrew A, et al. Strategies for treatment of SSRI-associated sexual dysfunction: A survey of an academic psychopharmacology practice. [References]. Harv Rev Psychiatry. 2002;10(2):109-114. [pmid: 11897751].
Wespes E, Amar E, Hatzichristou D, et al. Guidelines on erectile dysfunction. Eur Urol. 2002;41(1):1-5. [pmid: 11999460].
Wincze John P, Carey Michael P. Sexual dysfunction: A guide for assessment and treatment. 1991;xii-212.

## Comment/opinion piece

Akhtar Qureshi N, li Al-Habeeb T, Sayeed Al-Ghamdy Y. Sildenafil citrate (Viagra(TM)): Pros and cons!. Saudi Pharmaceutical Journal. 1999;7(4):192-200.
Anonymous. Editor's comment. BJU Int 2002;89(9):i-ii.
Aversa A, Fabbri A. New oral agents for erectile dysfunction: What is changing in our practice?. Asian J Androl. 2001;3(3):175-179. [pmid: 11561186].
Bahnson RR. Papaverine hydrochloride in peripheral blood and the degree of penile erection: Editorial comment. Br J Urol. 1990;143(6):1137.
Bancroft J. Hormones and human sexual behavior. J Sex Marital Ther. 1984;10(1):3-21. [pmid: 6708115].
Bancroft J. Are the effects of androgens on male sexuality noradrenergically mediated? Some consideration of the human. Neuroscience & Biobehavioral Reviews. 1995;19(2):325-330. [pmid: 7630586].
Benet AE, Sharaby JS, Melman A. Male erectile dysfunction assessment and treatment options. [Review] [15 refs]. Compr Ther. 1994;20(12):669-673. [pmid: 7882650].
Braunstein GD. Endocrine causes of impotence. Optimistic outlook for restoration of potency. Postgrad Med. 1983;74(4):207-217. [pmid: 6622311].
Carosa E, Lombardo F, Martini P, et al. The therapeutic dilemma: How to use tadalafil. International Journal of Andrology Supplement. 2005;28(2):74-80.
Carosa E, Volpe R, Martini P, et al. Psychosocial issues of ART in aging male. [Review] [37 refs]. J Endocrinol Invest. 2005;28(3 Suppl):117-121. [pmid: 16042370].
Cartledge J, Eardley I. Sildenafil. Expert Opin Pharmacother. 1999;1(1):137-147. [pmid: 11249556].
Cohan P, Korenman SG. Commentary: Erectile dysfunction. Journal of Clinical Endocrinology & Metabolism. 2001;86(6):2391-2394. [pmid: 11397828].
Dinsmore WW. Clinical aspects of erectile dysfunction. Int J STD AIDS. 1996;7(Suppl 3):2-4. [pmid: 8876371].
Eardley I. A multicenter, randomized, double-blind, crossover study to evaluate patient preference between tadalafil and sildenafil: Editorial comment. Eur Urol. 2004;45(4):507-508.
El-Sakka AI. Cardiovascular system as a ‘core’ of sexual life. Expert Opin Pharmacother. 2005;6(13):2223-2230. [pmid: 16218883].
Fabbri A, Aversa A. The therapeutic dilemma: How to use short-acting PDE5 inhibitor drugs. International Journal of Andrology Supplement. 2005;28(2):69-73.
Frajese G, Pozzi F. New achievements and pharmacotherapeutic approaches to impotence in the elderly. Aging-Clinical & Experimental Research. 2003;15(3):222-233. [pmid: 14582685].
Gold Mark S, Frost-Pineda Kimberly, Carnes Patrick J. Depression-Related Improvement With Vardenafil for Erectile Response. [References]. Am J Psychiatry. 2006;163(8):1449. [pmid: 16877666].
Gonzalez-Cadavid NF, Rajfer J. Therapeutic stimulation of penile nitric oxide synthase (NOS) and related pathways. Med Actual. 2000;36(23):163-174.
Gooren L. Testosterone supplementation: Why and for whom?. Aging Male. 2003;6(3):184-199. [pmid: 14628499].
Hall Kathryn S K, Leiblum Sandra R. Sexual dysfunction. Thase, Michael E (Ed); Edelstein, Barry A (Ed); Hersen, Michel (Ed) 1990;(1990):684
Holmes S. Treatment of male sexual dysfunction. Br Med Bull. 2000;56(3):798-808. [pmid: 11255563].
Horrigan Joseph P, Jarrett Barnhill L. “Priapism associated with venlafaxine use”: Comment. Journal of the American Academy of Child & Adolescent Psychiatry. 2000;39(1):16-17. [pmid: 10638063].
Incrocci L. Can you still have a sexual life after prostate cancer?. Br J Sex Med. 2006;3(SUPPL. 2):86.
Israel M. Viagra: The first oral treatment for impotence. Can Pharm J. 1998;261(7005):164-165.
Jefferson James W. “Psychotropic medications and their effects on sexual function: Diagnosis, biology, and treatment approaches”: Comment. Hillside J Clin Psychiatry. 1995;56(11):536-537.
Jockenhovel F, Kaufman JM, Mickisch GH, et al. The good, the bad, and the unknown of late onset hypogonadism: The urological perspective. The Journal of Mens Health & Gender. 2005;2(3):292-301.
Kalsi JS, Cellek S, Muneer A, et al. Current oral treatments for erectile dysfunction. Expert Opin Pharmacother. 2002;3(11):1613-1629. [pmid: 12437495].
Koeneman KS, Mulhall JP, Goldstein I. Sexual health for the man at midlife: In-office workup. Geriatrics. 1997;52(9):76-86. [pmid: 9307574].
Kulkarni SK, Reddy DS. Pharmacotherapy of male erectile dysfunction with sildenafil. Indian J Pharmacol. 1998;30(6):367-378.
Lakin M. The evaluation and nonsurgical management of impotence. Semin Nephrol. 1994;14(6):544-550. [pmid: 7855461].
Leungwattanakij S, Flynn V, Hellstrom WJG. Intracavernosal injection and intraurethral therapy for erectile dysfunction. Urol Clin North Am. 2001;28(2):343-354. [pmid: 11402586].
Lewis JH. Treatment options for men with sexual dysfunction. J ET Nurs. 1992;19(4):131-142. [pmid: 1637912].
Liss HK, Elmore JG. Radical prostatectomy versus watchful waiting.[comment]. N Engl J Med. 2005;353(12):1298-1300. [pmid: 16180273].
Lue TF. The clinical evaluation of the patient presenting with erectile dysfunction: What is reasonable? Editorial comment. Br J Urol. 1990;144(5):1310.
Lue TF, Khoury S. Comments on the Second International Consultation on Erectile and Sexual Dysfunctions. Br J Sex Med. 2004;1(1):4-5.
Lue T, Goldstein I, Traish A. Comparison of oral and intracavernosal vasoactive agents in penile erection. [Review][35 refs]. Int J Impot Res 2000;12Suppl-88.
Marks LS. Efficacy of tadalafil for the treatment of erectile dysfunction at 24 and 36 hours after dosing: A randomized controlled trial: Editorial comment 1. Urology. 2003;62(1):125-126.
Meinhardt W. Vardenafil: A viewpoint. Drugs Aging. 2002;19(3):228-229.
Melman A, Christ GJ. The hemodynamics of erection and the pharmacotherapies of erectile dysfunction. Heart Dis. 2002;4(4):252-264. [pmid: 12147185].
Meuleman EJ. Editorial comment. Eur Urol. 2005;47(4):529.
Mikhailidis DP, Khan MA, Milionis HJ, et al. The treatment of hypertension in patients with erectile dysfunction. Current Medical Research & Opinion, Supplement. 1999;16(1):s31-s36.
Mobley DF, Baum N. When patients request the impotence pill: Tips for office evaluation and treatment. Postgrad Med. 1998;104(2):55-66. [pmid: 9721579].
Montague DK. Editorial: Medical therapies for erectile dysfunction. Br J Urol. 1999;162(3 I):732.
Morales A. Yohimbine in erectile dysfunction: The facts. Int J Impot Res. 2000;12(SUPPL. 1):S70-S74.
Morales A, Buvat J, Gooren LJ, et al. Endocrine aspects of sexual dysfunction in men. Br J Sex Med. 2004;1(1):69-81.
Morgentaler A. Male impotence. Lancet. 1999;354(9191):1713-1718. [pmid: 10568586].
Novak A, Brod M, Elbers J. Andropause and quality of life: findings from patient focus groups and clinical experts. Maturitas. 2002;43(4):231-237. [pmid: 12468130].
Nurnberg HG, Hensley PL. Selective phosphodiesterase type-5 inhibitor treatment of serotonergic reuptake inhibitor antidepressant-associated sexual dysfunction: A review of diagnosis, treatment, and relevance. CNS Spectr. 2003;8(3):194-202. [pmid: 12595814].
Perimenis P. Editorial comment on the manuscript entitled ‘comparison of clinical trials with sildenafil, vardenafil and tadalafil in erectile dysfunction’. Expert Opin Pharmacother. 2005;6(1):1-2. [pmid: 15709877].
Rivas David A, Chancellor Michael B. Management of erectile dysfunction. Sipski, Marca L (Ed); Alexander, Craig J (Ed) 1997;(1997):651
Rivera R, Cohen MS. Erectile dysfunction: Which medical option for which patient?. Consultant. 2006;46(10):1187-1195.
Sadovsky R, Dunn M, Grobe BM. Erectile dysfunction: The primary care practitioner's view. Am J Manag Care. 1999;5(3):333-341. [pmid: 10351029].
Sampaio F. Combination of phosphodiesterase-5 inhibitors and alpha-blockers in patients with benign prostatic hyperplasia: Treatments of lower urinary tract symptoms, erectile dysfunction, or both? Editorial comment. International Braz J Urol. 2006;32(1):114.
Segraves RT. Pharmacologic management of sexual dysfunction: Benefits and limitations. CNS Spectr. 2003;8(3):225-229. [pmid: 12595817].
Slob AK. Age, libido, and male sexual function. Prostate Suppl. 2000;45(SUPPL. 10):9-13. [pmid: 11056487].
Star CH, Hobdy-Henderson KC, Mulhall JP. New and Emerging Therapies for Erectile Dysfunction. Drug Topics. 2000;144(SUPPL. JUNE):3-14.
Steers WD. The future direction of neuro-urology drug research. Current Opinion in Central & Peripheral Nervous System Investigational Drugs. 2000;2(3):268-282.
Stein Michael. Viagra and cluster headache. Headache: The Journal of Head and Face Pain. 1999;39(1):58-59.
Stern MF. Erectile dysfunction in older men. Topics in Geriatric Rehabilitation. 1997;12(4):40-52.
Studd JWW, Cronje WH. Androgens and libido: A case for men and women. J Br Menopause Soc. 2001;7(SUPPL. 2):19-21.
Swerdloff R. Testosterone levels in benign prostatic hyperplasia: Sexual function and response to therapy with dutasteride: Commentary. Nature Clinical Practice Urology. 2006;3(10):528-529.
Tan RS. Novel treatment options for overlapping yet distinct erectile dysfunction and andropause syndromes. Curr Opin Investig Drugs. 2003;4(4):435-438.
Tan RS, Pu SJ. Is it andropause? Recognizing androgen deficiency in aging men.[see comment]. Postgrad Med. 2004;115(1):62-66. [pmid: 14755879].
Thomas AM, LoPiccolo J. Sexual functioning in persons with diabetes: Issues in research, treatment, and education. Clin Psychol Rev. 1994;14(1):61-86.
Trost L, Kendirci M, Hellstrom WJG. Erectile dysfunction in the aging man: Current options for treatment. Aging Health. 2006;2(1):71-86.
Walsh PC. Re: Quality of life: radical prostatectomy versus radiation therapy for prostate cancer.[comment]. Br J Urol. 1996;155(6):2038-2039.
Wang XW. Weige. Treatment of erectile dysfunction. Drugs of the Future. 1999;24(7):747-749.
Wyllie M G. Clinical trials design: protocols and endpoints. Int J Impot Res 2000;12Suppl-8.

## Letter to the editor

Anonymous. Bashing beta blockers' bad rap. Harv Heart Lett 2002;13(2):7
Garg R, Karlawish JHT, Casarett D, et al. Sildenafil for diabetic men with erectile dysfunction [3] (multiple letters). J Am Med Assoc. 1999;282(10):939-941.
Gould D. Letter to the Editor [2]. Int J Impot Res. 1999;11(4):237-238. [pmid: 10467525].
Malozowski S, Sahlroot JT, Herrmann HC. Hemodynamic effects of sildenafil [2] (multiple letters). N Engl J Med. 2000;343(13):967-968. [pmid: 11012322].
Pomara G, Morelli G. Re: Tadalafil has no detrimental effect on human spermatogenesis or reproductive hormones [14] (multiple letters). Br J Urol. 2004;171(6 I):2390-2391.
Rosen R. Editorial comment. Eur Urol. 2004;46(6):774-775.
Wicker PA, Siegel R, Marks LS. Treatment of erectile dysfunction with sildenafil [1] (multiple letters). Urology. 1999;53(5):1070-1071. [pmid: 10223508].

## Not an original study

Althof Stanley E, O'Leary Michael P, et al. Self-Esteem, Confidence, and Relationships in Men Treated with Sildenafil Citrate for Erectile Dysfunction. [References]. J Gen Intern Med. 2006;21(10):1069-1074. [pmid: 16836626].
Anon Anonymous. Sildenafil: an oral drug for impotence. Med Lett Drugs Ther 1998;40(1026):51–52.
Aversa A, Bruzziches R, Pili M, et al. Phosphodiesterase 5 inhibitors in the treatment of erectile dysfunction. Curr Pharm Des. 2006;12(27):3467-3484. [pmid: 17017940].
Bach Dilello, Amy K. The enhancing effects of manualized treatment for erectile dysfunction among men using sildenafil: A preliminary investigation. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2003;64(5-B):2003. pp.
Banner Linda L. The effects of collaborative care in the treatment of erectile dysfunction (ED): An integrative treatment protocol (ITP). Dissertation Abstracts International: Section B: The Sciences and Engineering. 2001;61(12-B):2001. pp.
Barrett Peter. Impotence: The referred patient. Lincoln, Rosemarie (Ed) 1992;(1992):193
Broderick GA, Donatucci CF, Hatzichristou D, et al. Efficacy of tadalafil in men with erectile dysfunction naive to phosphodiesterase 5 inhibitor therapy compared with prior responders to sildenafil citrate. Br J Sex Med. 2006;3(4):668-675.
Campbell HE. Clinical monograph for drug formulary review: erectile dysfunction agents. [Review] [64 refs]. Journal of Managed Care Pharmacy. 2005;11(2):151-171. [pmid: 15766322].
Carey Michael P, Lantinga Larry J, Krauss Dennis J. Male erectile disorder. Hersen, Michel (Ed); Ammerman, Robert T (Ed) 1994;(1994):512
Delate T, Simmons VA, Motheral BR. Patterns of use of sildenafil among commercially insured adults in the United States: 1998-2002. Int J Impot Res. 2004;16(4):313-318. [pmid: 14973524].
Ganem JP, Lucey DT, Janosko EO, et al. Unusual complications of the vacuum erection device. [Review] [17 refs]. Urology. 1998;51(4):627-631. [pmid: 9586618].
Kachhi PN, Henderson SO. Priapism after androstenedione intake for athletic performance enhancement. Ann Emerg Med. 2000;35(4):391-393. [pmid: 10736127].
Kloner RA, Jackson G, Hutter AM, et al. Cardiovascular safety update of Tadalafil: retrospective analysis of data from placebo-controlled and open-label clinical trials of Tadalafil with as needed, three times-per-week or once-a-day dosing. Am J Cardiol. 2006;97(12):1778-1784. [pmid: 16765134].
Leiblum Sandra R, Rosen Raymond C. Principles and practice of sex therapy (3rd ed.). (2000) 2000;xiv, 514 pp. New York, NY, US514
Melman A, Serels S, Morales Wessells, et al. Priapism. Int J Impot Res. 2000;12(SUPPL. 4):S133-S139. [pmid: 11035401].
Musacchio Najah S, Hartrich Molly, Garofalo Robert, et al. Erectile Dysfunction and Viagra Use: What's up with College-Age Males? [References]. J Adolesc Health. 2006;39(3):452-454. [pmid: 16919814].
Oettel M. Report on the satelite symposium, the role of testosterone in erectile function, held at the 7th congress of the European society for sexual medicine (5–8 December 2004, London UK). The Journal of Mens Health & Gender. 2005;2(2):263-265.
Padma-Nathan H, Christ G, Adaikan G, et al. Pharmacotherapy for erectile dysfunction. Br J Sex Med. 2004;1(2):128-140.
Pescatori ES, Drei B, Morgia G, et al. Salvaging the oral treatment failure patient. Current Sexual Health Reports. 2006;3(1):20-24.
Rosen Raymond C. Medical and psychological interventions for erectile dysfunction: Toward a combined treatment approach. Leiblum, Sandra R (Ed); Rosen, Raymond C (Ed) 2000;(2000):514
Salem EA, Kendirci M, Hellstrom WJG. Drug evaluation: Udenafil, a long-acting PDE5 inhibitor for erectile dysfunction. Curr Opin Investig Drugs. 2006;7(7):661-669.
Sam R, Patel P. Sildenafil in dialysis patients. Int J Artif Organs. 2006;29(3):264-268. [pmid: 16685669].
Segraves Taylor, Althof Stanley. Psychotherapy and pharmacotherapy for sexual dysfunctions. [References]. Nathan, Peter E (Ed); Gorman, Jack M (Ed) 2002;(2002):681
Sobel RE, Cappelleri JC. NAION and treatment of erectile dysfunction: Reply from Pfizer [13]. Br J Ophthalmol. 2006;90(7):927. [pmid: 16782965].
Steidle CP, Stecher VJ, Pace C, et al. Correlation of improved erectile function and rate of successful intercourse with improved emotional well-being assessed with the Self-Esteem And Relationship questionnaire in men treated with sildenafil for erectile dysfunction and stratified by age. Current Medical Research & Opinion. 2006;22(5):939-948. [pmid: 16709315].
Weeks Gerald R, Gambescia Nancy. Erectile dysfunction: Integrating couple therapy, sex therapy, and medical treatment. (2000) 2000;xii, 201 pp. New York, NY, US201
Wlasowicz Grace, Saidel. Emotional and functional coping outcomes of men receiving pharmacologic erection therapy for impotence. Dissertation Abstracts International: Section B: The Sciences and Engineering 2002;62(8-B):Mar
Wysowski DK, Swann J. Use of medications for erectile dysfunction in the United States, 1996 through 2001. Br J Urol. 2003;169(3):1040-1042.

## Not an english publication

Albaugh JA. Intracavernosal injection algorithm. Urol Nurs. 2006;26(6):449-453. [pmid: 17253079].
Amr MM, Abbas EZ, El-Samra M, et al. Neuropsychiatric syndromes and occupational exposure to zinc phosphide in Egypt. Environ Res. 1997;73(12):200-206. [pmid: 9311548].
Baker Christine D. A cognitive-behavioural model for the formulation and treatment of sexual dysfunction. Ussher, Jane M (Ed); Baker, Christine D (Ed) 1993;(1993):272
Buddeberg C, Bucher T, Hornung R. [Erectile dysfunction in men in their second half of life]. [German]. Urologe (Ausg 1048;A).(9):1045–1046.
Buvat J, Amar E, Cambau O, et al. Double-blind multicenter study comparing Alprostadil Alfadex with moxisylyte chlorhydrate in patients with chronic erectile dysfunction. Andrologie. 1998;8(2):204-212.
Carlsen JE, Kober L, Torp-Pedersen CT, et al. The optimal dosage of bendrofluazide in hypertension. A randomized double-blind dosage-response investigation. OPTIMAL DOSIS AF BENDROFLUMETIAZID VED HYPERTENSION. EN RANDOMISERET DOBBELTBLIND DOSIS-RESPONSUNDERSOGELSE. UGESKR LAEG. 1990;152(42):3072-3075. [pmid: 2238184].
Carmignani G, Oneto F. Medical therapy of prostate carcinoma. Minerva Urol Nefrol. 2004;56(2):147-163. [pmid: 15195023].
Chueh SC, Yu HJ, Chiu TY, et al. Treating benign prostatic hyperplasia with finasteride in Chinese men: one-year experience. J Formos Med Assoc. 1996;95(8):650-652. [pmid: 8870441].
Cushman WC, Cohen JD, Jones RP, et al. Comparison of the fixed combination of enalapril/diltiazem ER and their monotherapies in stage 1 to 3 essential hypertension. American journal of hypertension : journal of the American Society of Hypertension. 1998;11(1 Pt 1):23-30.
East Marion L, Hofer Heribert, Wickler Wolfgang. The erect ‘penis’ is a flag of submission in a female-dominated society: Greetings in Serengeti spotted hyenas. Behav Ecol Sociobiol. 1993;33(6):355-370.
Fietkau R, Riepl M, Kettner H, et al. Supportive treatment with megestrol acetate during radio-(chemo-) therapy. A randomized trial. Sonderb Z Strahlenther Onkol. 1996;172(3):162-168.
Furusyo N, Hayashi J, Ueno K, et al. Human lymphoblastoid interferon treatment for patients with hepatitis C virus-related cirrhosis. Clin Ther. 1997;19(6):1352-1367. [pmid: 9444445].
Gupta A, Cohen BH, Ruggieri P, et al. Phase I study of thalidomide for the treatment of plexiform neurofibroma in neurofibromatosis 1. Neurology. 2003;60(1):130-132. [pmid: 12525736].
Hampson S, Kessel D. Colour Doppler and cavernosometry in the evaluation of impotence [abstract]. Br-J-Radiol 1991;64
Lai XP. [Treatment of 76 cases of impotence by acupuncture and point injection]. Shanghai Journal of Acupuncture and Moxibustion. 1994;13(1):14.
Lepola U, Heikkinen H, Rimon R, et al. Clinical evaluation of alprazolam in patients with panic disorder: A double-blind comparison with imipramine. Hum Psychopharmacol. 1990;5(2):159-163.
Merkel C, Marin R, Enzo E, et al. Randomised trial of nadolol alone or with isosorbide mononitrate for primary prophylaxis of variceal bleeding in cirrhosis. Lancet. 1996;348(9043):1677-1681. [pmid: 8973428].
Nickel JC. Placebo therapy of benign prostatic hyperplasia: a 25-month study. Canadian PROSPECT Study Group. Br J Urol. 1998;81(3):383-387. [pmid: 9523656].
Ribq N, Rajmil O, Bassas L, et al. Response to intracavernosal administration of three different drugs in the same group of patients with erectile dysfunction. Arch Esp Urol. 2001;54(4):355-359. [pmid: 11455770].
Rosen RC, Fisher WA, Beneke M, et al. The COUPLES-project: a pooled analysis of patient and partner treatment satisfaction scale (TSS) outcomes following vardenafil treatment. BJU Int. 2007;99(4):849-859. [pmid: 17378845].
Rowland David L, Haensel Stefan M, Blom Jan H, et al. Penile sensitivity in men with premature ejaculation and erectile dysfunction. J Sex Marital Ther. 1993;19(3):189-197. [pmid: 8246274].
Samli MM, Dincel C. Terazosin and doxazosin in the treatment of BPH: Results of a randomized study with crossover in non-responders. Urol Int. 2004;73(2):125-129. [pmid: 15331896].
Sanchez D J, Rodriguez P L, Navarro A et al. Comparative treatment of primary hypercholesterolemia with lovostatin or bezafibrate. Randomized and double blind study. TRATAMIENTO COMPARATIVO DE LA HIPERCOLESTEROLEMIA PORIMARIA CON LOVOSTATINA Y BEZAFIBRATO. ENSAYO RANDOMIZADO Y A DOBLE CIEGO. REV 1991;ESP. CARDIOL. 44(4):251–257.
Summerbell CD, Youle M, McDonald V, et al. Megestrol acetate vs cyproheptadine in the treatment of weight loss associated with HIV infection. Int J STD AIDS. 1992;3(4):278-280. [pmid: 1504160].
Swindle R, Cameron A, Rosen R. A 15-item short form of the Psychological and Interpersonal Relationship Scales. Int J Impot Res. 2006;18(1):82-88. [pmid: 16163372].
Unger T. Lessons from ALLHAT: Are low budget diuretics first line therapy in hypertension?. Z Kardiol. 2004;93(5):349-356. [pmid: 15160270].
Van D V L L, Brouwer J, Portegies M et al. Effect and safety of bisoprolol (Emcor (R)) and isosorbidedinitrate in the treatment of angina pectoris. DE EFFECTIVITEIT EN VEILIGHEID VAN BISOPROLOL (EMCOR (R)) EN ISOSORBIDEDINITRATEN BIJ DE BEHANDELING VAN ANGINA PECTORIS. Belg Tijdschr Geneesk 1993;THER. GENEESM. ONDERZ. 18(5):138–141.
Velasco M, Urbina A, Silva H, et al. A double-blind, parallel, comparative evaluation of amlodipine vs. captopril in the monotherapeutic treatment of mild and moderate essential hypertension. J Cardiovasc Pharmacol. 1991;17(SUPPL. 1):S19-S21. [pmid: 16296701].
Yeni E, Unal D, Verit A, et al. Minimal transurethral prostatectomy plus bladder neck incision versus standard transurethral prostatectomy in patients with benign prostatic hyperplasia: a randomised prospective study. Urol Int. 2002;69(4):283-286. [pmid: 12444284].

## Not a relavant study

Annual update 2004/2005 - Treatment of genitourinary disorders. Drugs of the Future 2005;30(9):931–934.
Abrams J. Time course of the interaction between tadalafil and nitrates.[comment]. J Am Coll Cardiol. 2004;43(11):2150-2151. [pmid: 15172433].
Adaikan PG, Chong YS, Chew SSL, et al. Male sexual dysfunction. Curr Obstet Gynaecol. 2000;10(1):23-28.
Adams MA, Perdok RJ, Padley RJ, et al. Safety and tolerability of apomorphine SL in men with cardiovascular disorders. European Urology Supplements. 2002;1(3):28-32.
Ahl J, Kinon B J, Liu-Seifert H. Sexual dysfunction associated with neuroleptic-induced hyperprolactinemia improves with reduction in prolactin levels. Ann N Y Acad Sci 2004;1032(pp 289–290):-290.
Ahuja SK, Krane NK, Hellstrom WJ. Penile prostheses in the management of impotence in patients with end-stage renal disease. J La State Med Soc. 1998;150(1):32-34. [pmid: 9448384].
Akbari F, Alavi M, Esteghamati A, et al. Effect of renal transplantation on sperm quality and sex hormone levels. BJU Int. 2003;92(3):281-283. [pmid: 12887484].
Akkus E, Kadioglu A, Esen A, et al. Prevalence and correlates of erectile dysfunction in Turkey: a population-based study. Eur Urol. 2002;41(3):298-304. [pmid: 12180232].
Alexandre B, Lemaire A, Desvaux P, et al. Intracavernous injections of prostaglandin E1 for erectile dysfunction: patient satisfaction and quality of sex life on long-term treatment. Br J Sex Med. 2007;4(2):426-431.
Alfonso A, Rieniets KI, Vigersky RA. Incidence and clinical significance of elevated macroprolactin levels in patients with hyperprolactinemia. Endocr Pract. 2006;12(3):275-280. [pmid: 16772199].
Alivizatos G, Skolarikos A, Laguna P. Recent data upon impotence, incontinence and quality of life issues concerning radical prostatectomy. [Review] [74 refs]. Arch Esp Urol. 2003;56(3):321-330. [pmid: 12768997].
Allan CA, McLachlan RI. Age-related changes in testosterone and the role of replacement therapy in older men. Clin Endocrinol (Oxf). 2004;60(6):653-670. [pmid: 15163327].
Althof SE. Quality of life and erectile dysfunction. Urology. 2002;59(6):803-810. [pmid: 12031357].
Althof SE, Corty EW, Levine SB, et al. EDITS: development of questionnaires for evaluating satisfaction with treatments for erectile dysfunction. Urology. 1999;53(4):793-799. [pmid: 10197859].
Althof Stanley E, Turner Louisa A. Self-injection therapy and external vacuum devices in the treatment of erectile dysfunction: Methods and outcome. Rosen, Raymond C (Ed); Leiblum, Sandra Risa (Ed) 1992;(1992):378
Altwein JE, Keuler FU. Oral treatment of erectile dysfunction with apomorphine SL. [Review] [34 refs]. Urol Int. 2001;67(4):257-263. [pmid: 11741126].
Anderson RA, Bancroft J, Wu FC. The effects of exogenous testosterone on sexuality and mood of normal men. Journal of Clinical Endocrinology & Metabolism. 1992;75(6):1503-1507. [pmid: 1464655].
Anderson RA, Martin CW, Kung AW, et al. 7Alpha-methyl-19-nortestosterone maintains sexual behavior and mood in hypogonadal men. Journal of Clinical Endocrinology & Metabolism. 1999;84(10):3556-3562. [pmid: 10522995].
Anderson RA, Wallace AM, Sattar N, et al. Evidence for tissue selectivity of the synthetic androgen 7 alpha-methyl-19-nortestosterone in hypogonadal men. Journal of Clinical Endocrinology & Metabolism. 2003;88(6):2784-2793. [pmid: 12788888].
Andersson KE. Pharmacology of penile erection. Pharmacol Rev. 2001;53(3):417-450. [pmid: 11546836].
Andolsek KM. Alprostadil for the treatment of erectile dysfunction. Am Fam Physician. 1997;55(5):1902-1903.
Andriole G, Bruchovsky N, Chung LWK, et al. Dihydrotestosterone and the prostate: The scientific rationale for 5a-reductase inhibitors in the treatment of benign prostatic hyperplasia. Br J Urol. 2004;172(4 I):1399-1403.
Anonymous. Tadalafil: new preparation. Slightly more convenient, but poorly assessed in organic disorders. Prescrire Int 2003;12(68):213–215.
Anonymous. Tadalafil (cialis) for erectile dysfunction. Medical Letter on Drugs & Therapeutics 2003;45(1172):101–102.
Anonymous. Vardenafil (levitra) for erectile dysfunction. Medical Letter on Drugs & Therapeutics 2003;45(1166):77–78.
Anonymous. First study of Viagra in black men demonstrates effective, well-tolerated treatment. Urol Nurs 2002;22(4):285–286.
Anonymous. Study shows patients taking vardenafil consistently completed sexual intercourse. Urol Nurs 2001;21(6):413–414.
Anonymous. Apomorphine (TAP holdings). 6a beta-aporphine-10,11-diol hydrochloride hemihydrate, apomorphine hydrochloride, spontane, Uprima. Drugs in R & D 1999;2(6):415–416.
Anonymous. Intraurethral alprostadil for impotence. Medical Letter on Drugs & Therapeutics 1997;39(997):32
Anonymous. Treatment for impotence gains FDA approval. Am J Health Syst Pharm 1995;52(19):2078–2079.
Anonymous. Intracavernous injection of alprostadil for erectile dysfunction. Medical Letter on Drugs & Therapeutics 1995;37(958):83–84.
Anonymous. Vardenafil works for 10 hours. Can Pharm J 2005;275(7360):133
Anonymous. Treatment duration of action is important in ED. Can Pharm J 2004;273(7330):878
Anonymous. Dutaseride. Prescrire Int 2004;13(73):183
Anonymous. Erratum: Efficacy and tolerability of sildenafil in Indian males with erectile dysfunction: A double-blind, randomized, placebo controlled, crossover study (Indian Journal of Pharmacology (2004) vol. 37 (5) (317)). Indian J Pharmacol 2004;36(6):391
Anonymous. Partnership struck between Bayer and Schering. Nat Rev Genet 2004;3(10):819
Anonymous. Erectile dysfunction drugs may reduce fertility but help depression. Can Pharm J 2004;272(7294):439
Anonymous. Sildenafil appears safe and effective for some heart failure patients. Can Pharm J 2004;272(7290):310
Anonymous. What to do when oral treatment fails?. Int J Impot Res 2003;15(SUPPL. 7):S30-S32.
Anonymous. Oral drug treatment of erectile dysfunction. Int J Impot Res 2003;15(SUPPL. 7):S27-S29.
Anonymous. Counselling and increased dose of sildenafil improves response in ED. British Journal of Diabetes & Vascular Disease 2003;3(6):445
Anonymous. Improve erectile function early after prostatectomy. Med Today 2003;4(11):8–9.
Anonymous. Recent FDA approval of new erectile dysfunction drug provides first challenge to sildenafil. Geriatrics and Aging 2003;6(8):11
Anonymous. Inhaled apomorphine promising for erectile dysfunction treatment. Can Pharm J 2003;271(7261):170
Anonymous. Transurethral alprostadil. Prescrire Int 2002;11(61):144
Anonymous. IDdb News focus. Current Drug Discovery 2003;(pp 10–13):-13.
Anonymous. Vardenafil prolongs improved erectile function in diabetics. Cardiology Review 2002;19(10):38–39.
Anonymous. Erectile dysfunction treated effectively with tadalafil. Economics of Neuroscience 2001;3(11):19
Anonymous. New erectile dysfunction drug useful in diabetes. Can Pharm J 2001;267(7173):669
Anonymous. Erectile dysfunction - Alprostadil. Manuf Chem Aerosol News 2001;72(11):21
Anonymous. Erectile dysfunction - Vardenafil. Manuf Chem Aerosol News 2001;72(6):25
Anonymous. FDA approves oral therapy for erectile dysfunction. Am J Health Syst Pharm 1998;55(10):981–984.
Anonymous. Sildenafil Viagra(R) UK-92480: Treatment of erectile dysfunction phosphodiesterase V inhibitor. Drugs of the Future 1998;23(2):242–243.
Anonymous. Intracavernosal alprostadil for erectile dysfunction. Hospital Practice (Office Edition) 1996;31(8):136–137.
Anonymous. Intracavernous alprostadil: Effective therapy for erectile dysfunction. Drugs & Therapy Perspectives 1996;7(6):1–5.
Anonymous. Heart drug with ‘viagra side-effect’. Indian J Med Sci 1999;53(5):236
Anonymous. What to do if Viagra won't do. Harvard Mens Health Watch 2005;9(10):4–8.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: intracavernous injection of prostaglandin E1. JAMA 1991;265(24):3321–3323.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: papaverine and phentolamine. JAMA 1990;264(6):752–754.
Ansong KS, Punwaney RB. An assessment of the clinical relevance of serum testosterone level determination in the evaluation of men with low sexual drive. Br J Urol. 1999;162(3 I):719-721.
Ansong KS, Lewis C, Jenkins P, et al. Epidemiology of erectile dysfunction: a community-based study in rural New York State. Ann Epidemiol. 2000;10(5):293-296. [pmid: 10942877].
Arafa M, Eid H, Shamloul R. Significance of phentolamine redosing during prostaglandin E1 penile color Doppler ultrasonography in diagnosis of vascular erectile dysfunction. Int J Urol. 2007;14(5):476-477. [pmid: 17511742].
Araujo AB, O'Donnell AB, Brambilla DJ, et al. Prevalence and incidence of androgen deficiency in middle-aged and older men: Estimates from the Massachusetts male aging study. Journal of Clinical Endocrinology & Metabolism. 2004;89(12):5920-5926. [pmid: 15579737].
Araujo Andre B, Durante Richard, Feldman Henry A, et al. The relationship between depressive symptoms and male erectile dysfunction: Cross-sectional results from the Massachusetts male aging study. Psychosom Med. 1998;60(4):458-465. [pmid: 9710291].
Arnavaz A, Aurich A, Weissenborn K, et al. Effect of sildenafil (Viagra) on cerebral blood flow velocity: a pilot study. Psychiatry Res. 2003;122(3):207-209. [pmid: 12694895].
Arnold R, Beer D, Bhalay G, et al. 8-Aryl xanthines potent inhibitors of phosphodiesterase 5. Bioorg Med Chem Lett. 2002;12(18):2587-2590. [pmid: 12182866].
Aronson JK. Features of this month's Journal. Br J Clin Pharmacol. 2003;55(4):327-328.
Arslan D, Esen AA, Secil M, et al. A new method for the evaluation of erectile dysfunction: sildenafil plus Doppler ultrasonography. Br J Urol. 2001;166(1):181-184.
Arthur R. Cardiovascular disorders and erectile dysfunction. British Journal of Cardiology. 2002;9(3):144-145.
Ashok S, Sigman M. Bioavailable testosterone should be used for the determination of androgen levels in infertile men. Br J Urol. 2007;177(4):1443-1446.
Ashton AK, Jamerson BD, Weinstein WL, et al. Antidepressant-related adverse effects impacting treatment compliance: Results of a patient survey. Current Therapeutic Research, Clinical & Experimental. 2005;66(2):96-106.
Atala A. What's new in urology. J Am Coll Surg. 2004;199(3):446-461. [pmid: 15325616].
Atikeler MK, Gecit I, Senol FA. Optimum usage of prilocaine-lidocaine cream in premature ejaculation. Andrologia. 2002;34(6):356-359. [pmid: 12472618].
Atmaca M, Kuloglu M, Tezcan E. A new atypical antipsychotic: quetiapine-induced sexual dysfunctions. Int J Impot Res. 2005;17(2):201-203. [pmid: 15284834].
Avasthi A, Basu D, Kulhara P, et al. Psychosexual dysfunction in Indian male patients: Revisited after seven years. Arch Sex Behav. 1994;23(6):685-695. [pmid: 7872862].
Aversa A, Mazzilli F, Rossi T, et al. Effects of sildenafil (Viagra) administration on seminal parameters and post-ejaculatory refractory time in normal males. Hum Reprod. 2000;15(1):131-134. [pmid: 10611201].
Aydin S, Unal D, Erol H, et al. Multicentral clinical evaluation of the aetiology of erectile dysfunction: a survey report. International Urology & Nephrology. 2001;32(4):699-703. [pmid: 11989568].
Ayub W, Fletcher S. End-stage renal disease and erectile dysfunction. Is there any hope?. Nephrology Dialysis Transplantation. 2000;15(10):1525-1528.
Bagatell CJ, Heiman JR, Rivier JE, et al. Effects of endogenous testosterone and estradiol on sexual behavior in normal young men.[erratum appears in J Clin Endocrinol Metab 1994 Jun;78(6):1520]. Journal of Clinical Endocrinology & Metabolism. 1994;78(3):711-716. [pmid: 8126146].
Baggaley MR, Hirst JF, Watson JP. Outcome of patients referred to a psychosexual clinic with erectile failure. Sexual & Marital Therapy. 1996;11(2):123-130.
Bai WJ, Zhu JC, Jiang H, et al. [A comparative study of different vasoactive drugs in the treatment of impotence]. Chinese Journal of Urology. 1992;13(6):453-455.
Bailey J, Evans JP, Hardy M, et al. Synopsis: 2005 Annual Meeting of the American Society of Andrology. J Androl. 2005;26(6):678-688. [pmid: 16291961].
Bain J. Andropause. Testosterone replacement therapy for aging men. [Review] [55 refs]. Can Fam Physician. 2001;47:91-97. [pmid: 11212438].
Balon Richard. Sildenafil and sexual dysfunction associated with antidepressants. [References]. J Sex Marital Ther. 1999;25(4):259-264. [pmid: 10546162].
Bancroft J, Gutierrez P. Erectile dysfunction in men with and without diabetes mellitus: a comparative study.[see comment]. Diabet Med. 1996;13(1):84-89. [pmid: 8741818].
Bancroft J, Munoz M, Beard M, et al. The effects of a new alpha-2 adrenoceptor antagonist on sleep and nocturnal penile tumescence in normal male volunteers and men with erectile dysfunction. Psychosom Med. 1995;57(4):345-356. [pmid: 7480564].
Baniel J, Israilov S, Segenreich E, et al. Comparative evaluation of treatments for erectile dysfunction in patients with prostate cancer after radical retropubic prostatectomy. BJU Int. 2001;88(1):58-62. [pmid: 11446847].
Barnas J, Parker M, Guhring P, et al. The utility of tamsulosin in the management of orgasm-associated pain: a pilot analysis.[see comment]. Eur Urol. 2005;47(3):361-365. [pmid: 15716202].
Barqawi A, O'Donnell C, Kumar R, et al. Correlation between LUTS (AUA-SS) and erectile dysfunction (SHIM) in an age-matched racially diverse male population: data from the Prostate Cancer Awareness Week (PCAW). Int J Impot Res. 2005;17(4):370-374. [pmid: 15889121].
Bartlik Barbara D, Kaplan Peter, Kaplan Helen S. Psychostimulants apparently reverse sexual dysfunction secondary to selective serotonin re-uptake inhibitors. J Sex Marital Ther. 1995;21(4):264-271. [pmid: 8789508].
Bayes M, Rabasseda X, Prous JR. Gateways to Clinical Trials. Methods & Findings in Experimental & Clinical Pharmacology. 2004;26(9):723-753. [pmid: 15632957].
bdel-Khalek M, El-Hammady S, Ibrahiem el. A 4-year follow-up of a randomized prospective study comparing transurethral electrovaporization of the prostate with neodymium: YAG laser therapy for treating benign prostatic hyperplasia. BJU Int. 2003;91(9):801-805. [pmid: 12780836].
Beal K, Mears JG. Short report: Penile lymphoma following local injections for erectile dysfunction. Leuk Lymphoma. 2001;42(12):247-249. [pmid: 11699217].
Beard S, Hunn A, Wight J. Treatments for spasticity and pain in multiple sclerosis: A systematic review. Health Technol Assess. 2003;7(40):111p.
Beasley CM, Mitchell MI, Dmitrienko AA, et al. The combined use of ibutilide as an active control with intensive electrocardiographic sampling and signal averaging as a sensitive method to assess the effects of tadalafil on the human QT interval.[see comment]. J Am Coll Cardiol. 2005;46(4):678-687. [pmid: 16098435].
Becher E, Glina S. Erectile dysfunction in Latin America and treatment with sildenafil citrate (Viagra): Introduction. Int J Impot Res. 2002;14(SUPPL. 2):S1-S2. [pmid: 12161761].
Bella AJ, Brock GB. Tadalafil: A comprehensive update. Journal of Drug Evaluation. 2004;2(8):225-246.
Benson GS. The clinical evaluation of the patient presenting with erectile dysfunction: what is reasonable?. [Review] [27 refs]. Semin Urol. 1990;8(2):94-99. [pmid: 2191404].
Beretta G, Saltarelli O, Marzotto M, et al. Transcutaneous minoxidil in the treatment of erectile dysfunctions in spinal cord injured men. Acta Eur Fertil. 1993;24(1):27-30. [pmid: 8303971].
Berner M M, Kriston L, Harms A. Efficacy of PDE-5-inhibitors for erectile dysfunction. A comparative meta-analysis of fixed-dose regimen randomized controlled trials administering the International Index of Erectile Function in broad-spectrum populations. Int J Impot Res 2005;
Bestane WJ, Bestane MC, Ramos NA. Prospective study of sodium nitroprusside in pharmacologically induced erection. Braz J Urol. 2001;27(2):155-158.
Beutel ME, Wiltink J, Hauck EW, et al. Correlations between hormones, physical, and affective parameters in aging urologic outpatients. Eur Urol. 2005;47(6):749-755. [pmid: 15925068].
Bhatia MS, Malik SC. Dhat syndrome—a useful diagnostic entity in Indian culture. Br J Psychiatry. 1991;159(Nov.):691-695. [pmid: 1756347].
Bird TD, Lipe HP, Crabtree LD. Impotence associated with the Charcot-Marie-Tooth syndrome. Eur Neurol. 1994;34(3):155-157. [pmid: 8033941].
Bivalacqua TJ, Hellstrom WJG. Potential application of gene therapy for the treatment of erectile dysfunction. J Androl. 2001;22(2):183-190. [pmid: 11229791].
Black AM, Day AG, Morales A. The reliability of clinical and biochemical assessment in symptomatic late-onset hypogonadism: Can a case be made for a 3-month therapeutic trial?. BJU Int. 2004;94(7):1066-1070. [pmid: 15541129].
Blander DS, Sanchez-Ortiz RF, Broderick GA. Sex inventories: can questionnaires replace erectile dysfunction testing?. Urology. 1999;54(4):719-723. [pmid: 10510935].
Blanker MH, Thomas S, Bohnen AM. Systematic review of Viagra RCTs. Br J Gen Pract. 2002;52(477):329. [pmid: 11942454].
Boccon Gibod L. Is transurethral needle ablation a safe and effective treatment for lower urinary tract symptoms secondary to BPH?. Nature Clinical Practice Urology. 2004;1(1):24-25.
Bochinski DJ, Dean RC, Lue TF. Erectile dysfunction and priapism. Nat Clin Pract Urol. 2004;1(1):49-53. [pmid: 16474467].
Bodie JA, Beeman WW, Monga M. Psychogenic erectile dysfunction. Int J Psychiatry Med. 2003;33(3):273-293. [pmid: 15089008].
Bodie J, Lewis J, Schow D, et al. Laboratory evaluations of erectile dysfunction: an evidence based approach. Br J Urol. 2003;169(6):2262-2264.
Bodner DR, Leffler B, Frost F. The role of intracavernous injection of vasoactive medications for the restoration of erection in spinal cord injured males: a three year follow up. Paraplegia. 1992;30(2):118-120. [pmid: 1589286].
Bolona ER, Uraga MV, Haddad RM, et al. Testosterone use in men with sexual dysfunction: a systematic review and meta-analysis of randomized placebo-controlled trials. Mayo Clin Proc. 2007;82(1):20-28. [pmid: 17285782].
Boolell M, Allen MJ, Ballard SA, et al. Sildenafil: an orally active type 5 cyclic GMP-specific phosphodiesterase inhibitor for the treatment of penile erectile dysfunction. Int J Impot Res. 1996;8(2):47-52. [pmid: 8858389].
Boshier A, Wilton LV, Shakir SAW. Evaluation of the safety of sildenafil for male erectile dysfunction: Experience gained in general practice use in England in 1999. BJU Int. 2004;93(6):796-801. [pmid: 15049992].
Bouloux P. Testim 1% testosterone gel for the treatment of male hypogonadism. [Review] [33 refs]. Clin Ther. 2005;27(3):286-298. [pmid: 15878382].
Boydak B, Nalbantgil S, Fici F, et al. A randomised comparison of the effects of nebivolol and atenolol with and without chlorthalidone on the sexual function of hypertensive men. Clinical Drug Investigation. 2005;25(6):409-416. [pmid: 17532681].
Braatvedt GD. Outcome of managing impotence in clinical practice. N Z Med J. 1999;112(1092):272-274. [pmid: 10472891].
Brake M, Loertzer H, Horsch R, et al. Treatment of Peyronie's disease with local interferon-alpha 2b. BJU Int. 2001;87(7):654-657. [pmid: 11350406].
Bratus D, Hlebic G, Hajdinjak T. 16905960 of erectile dysfunction. Croat Med J. 2007;48(1):76-80. [pmid: 17309142].
Brazil M. Viagra for broken hearts?. Nat Rev Genet. 2005;4(3):190.
Brennemann W, Kohler W, Zierz S, et al. Testicular dysfunction in adrenomyeloneuropathy. Eur J Endocrinol. 1997;137(1):34-39. [pmid: 9242199].
Brennemann W, Stitz B, Van Ahlen H, et al. Treatment of idiopathic erectile dysfunction in men with the opiate antagonist naltrexone—a double-blind study. J Androl. 1993;14(6):407-410. [pmid: 8294223].
Briganti A, Chun FKH, Salonia A, et al. A comparative review of apomorphine formulations for erectile dysfunction: Recommendations for use in the elderly. Drugs Aging. 2006;23(4):309-319. [pmid: 16732690].
Briganti A, Salonia A, Gallina A, et al. Drug insight: Oral phosphodiesterase type 5 inhibitors for erectile dysfunction. Nature Clinical Practice Urology. 2005;2(5):239-247.
Briganti A, Salonia A, Zanni G, et al. Erectile dysfunction and radical prostatectomy: An update. Eau Update Series. 2004;2(2):84-92.
Brindis RG, Kloner RA. Sildenafil in patients with cardiovascular disease. [Review] [33 refs]. Am J Cardiol. 2003;92(9A):26M-36M. [pmid: 12842240].
Brixius K, Middeke M, Lichtenthal A, et al. Nitric oxide, erectile dysfunction and beta-blocker treatment (MR NOED study): Benefit of nebivolol versus metoprolol in hypertensive men. Clinical & Experimental Pharmacology & Physiology. 2007;34(4):327-331. [pmid: 17324145].
Broderick GA, Allen G, McClure RD. Vacuum tumescence devices: the role of papaverine in the selection of patients. Br J Urol. 1991;145(2):284-286.
Brooks DP, Giuliano F. Genitourinary diseases. Drug Discovery Today: Therapeutic Strategies. 2005;2(1):iii-iiv.
Brown JS, Wessells H, Chancellor MB, et al. Urologic complications of diabetes. Diabetes Care. 2005;28(1):177-185. [pmid: 15616253].
Buchholz NP, Weuste R, Mattarelli G, et al. Post-vasectomy erectile dysfunction. J Psychosom Res. 1994;38(7):759-762. [pmid: 7877130].
Buddeberg C, Bucher T, Hornung R. [Erectile dysfunction in men in their second half of life]. Urologe 2005;Ausg. A. 44(9):1045–1046, 1048–51.
Buena F, Swerdloff RS, Steiner BS, et al. Sexual function does not change when serum testosterone levels are pharmacologically varied within the normal male range. Fertility & Sterility. 1993;59(5):1118-1123. [pmid: 8486184].
Bukofzer S, Livesey N. Safety and tolerability of apomorphine SL (Uprima). Int J Impot Res. 2001;13(SUPPL. 3):S40-S44. [pmid: 11477491].
Burls A, Gold L, Clark W. Systematic review of randomised controlled trials of sildenafil (Viagra) in the treatment of male erectile dysfunction. Br J Gen Pract. 2001;51(473):1004-1012. [pmid: 11766850].
Burnett AL. Efficacy of tadalafil for the treatment of erectile dysfunction at 24 and 36 hours after dosing: A randomized controlled trial: Editorial comment 2. Urology. 2003;62(1):126.
Burnett AL. Vasoactive pharmacotherapy to cure erectile dysfunction: fact or fiction?. [Review] [45 refs]. Urology. 2005;65(2):224-230. [pmid: 15708027].
Burnett AL. The impact of sildenafil on molecular science and sexual health. Eur Urol. 2004;46(1):9-14. [pmid: 15183543].
Burns-Cox N, Gingell C. The andropause: fact or fiction?. [Review] [49 refs]. Postgrad Med J. 1997;73(863):553-556. [pmid: 9373594].
Buvat J. Hyperprolactinemia and sexual function in men: a short review. [Review] [26 refs]. Int J Impot Res. 2003;15(5):373-377. [pmid: 14562140].
Buvat J, Boujadoue G. Testosterone replacement therapy in the ageing man. The Journal of Mens Health & Gender. 2005;2(4):396-399.
Calof OM, Singh AB, Lee ML, et al. Adverse events associated with testosterone replacement in middle-aged and older men: A meta-analysis of randomized, placebo-controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60(11):1451-1457.
Campbell M. Beneficial cardiovascular effects and safety of sildenafil reported in trio of studies. Cardiology Review. 2001;18(6):27.
Cappelleri JC, Siegel RL, Glasser DB, et al. Relationship between patient self-assessment of erectile dysfunction and the sexual health inventory for men. Clin Ther. 2001;23(10):1707-1719. [pmid: 11726005].
Cara AM, Lopes-Martins RAB, Antunes E, et al. The role of histamine in human penile erection. Br J Urol. 1995;75(2):220-224. [pmid: 7850330].
Carani C, Bancroft J, Granata A, et al. Testosterone and erectile function, nocturnal penile tumescence and rigidity, and erectile response to visual erotic stimuli in hypogonadal and eugonadal men. Psychoneuroendocrinology. 1992;17(6):647-654. [pmid: 1287683].
Carani C, Scuteri A, Marrama P, et al. The effects of testosterone administration and visual erotic stimuli on nocturnal penile tumescence in normal men. Horm Behav. 1990;24(3):435-441. [pmid: 2227854].
Cardenas DD, Ditunno J, Graziani V, et al. Phase 2 trial of sustained-release fampridine in chronic spinal cord injury. Proc Annu Clin Spinal Cord Inj Conf. 2007;45(2):158-168.
Carey MP, Johnson BT. Effectiveness of yohimbine in the treatment of erectile disorder: four meta-analytic integrations. Arch Sex Behav. 1996;25(4):341-360. [pmid: 8836468].
Carey Michael P, Wincze John P, Meisler Andrew W. Sexual dysfunction: Male erectile disorder. Barlow, David H (Ed) 1993;(1993):534
Carosa E, Benvenga S, Trimarchi F, et al. Sexual inactivity results in reversible reduction of LH bioavailability. Int J Impot Res. 2002;14(2):93-99. [pmid: 11979323].
Carson CC. PNU-83757: a new agent for the treatment of erectile dysfunction.[comment]. Curr Urol Rep. 2002;3(6):465-466. [pmid: 12425868].
Carson CC, Burnett AL, Levine LA, et al. The efficacy of sildenafil citrate (Viagra) in clinical populations: an update. Urology. 2002;60(2 Suppl 2):12-27. [pmid: 12414330].
Carson CC, Hatzichristou DG, Carrier S. Erratum: Erectile response with vardenafil in sildenafil nonresponders: A multicentre, double-blind, 12-week, flexible-dose, placebo-controlled erectile dysfunction clinical trial (BJU International (2004) 94 (1301–1309)). BJU Int. 2005;96(3):466.
Carson CC, Rajfer J, Eardley I, et al. The efficacy and safety of tadalafil: an update. BJU Int. 2004;93(9):1276-1281. [pmid: 15180622].
Casella R, Deckart A, Bachmann A, et al. The patient's self-evaluation better predicts the degree of erectile dysfunction than the response to intracavernous alprostadil testing. Urol Int. 2004;72(3):216-220. [pmid: 15084765].
Caspi A, Goldenberg M M. Sildenafil: A new drug treatment for male erectile dysfunction. P & T 1998;23(5):
Cawello W, Schweer H, Dietrich B, et al. Pharmacokinetics of prostaglandin E1 and its main metabolites after intracavernous injection and short-term infusion of prostaglandin E1 in patients with erectile dysfunction. Br J Urol. 1997;158(4):1403-1407.
Cecchi M, Sepich CA, Felipetto R, et al. Vacuum constriction device and topical minoxidil for management of impotence. Arch Esp Urol. 1995;48(10):1058-1059. [pmid: 8588728].
Chaiban JT, Azar ST. Erectile dysfunction in diabetic patients. J Med Liban. 2004;52(4):217-219. [pmid: 16432985].
Chang DW, Wood CG, Kroll SS, et al. Cavernous nerve reconstruction to preserve erectile function following non-nerve-sparing radical retropubic prostatectomy: a prospective study. Keisei Geka. 2003;111(3):1174-1181.
Chatterjee R, Andrews HO, McGarrigle HH, et al. Cavernosal arterial insufficiency is a major component of erectile dysfunction in some recipients of high-dose chemotherapy/chemoradiotherapy for haematological malignancies. Bone Marrow Transplant. 2000;25(11):1185-1189. [pmid: 10849531].
Chatterjee R, Kottaridis PD, McGarrigle HH, et al. Management of erectile dysfunction by combination therapy with testosterone and sildenafil in recipients of high-dose therapy for haematological malignancies. Bone Marrow Transplant. 2002;29(7):607-610. [pmid: 11979311].
Chaudhuri TK, Fink S, Burger RH, et al. Nuclear penogram: Non-invasive technique to monitor and record effect of pharmacologically-induced penile erection in impotence therapy. Urology. 1990;35(1):98. [pmid: 2296828].
Cheitlin MD, Hutter AM, Brindis RG, et al. Use of sildenafil (Viagra) in patients with cardiovascular disease. Circulation. 1999;99(1):168-177. [pmid: 9884398].
Chen CT, Valicenti RK, Lu J, et al. Does hormonal therapy influence sexual function in men receiving 3D conformal radiation therapy for prostate cancer?. Int J Radiat Oncol Biol Phys. 2001;50(3):591-595. [pmid: 11395224].
Chen J, Greenstein A, Kaver I, et al. Use of automatic insulin injector for intracorporeal injection in erectile dysfunction. Br J Urol. 1994;152(2):461-462.
Chen J, Mabjeesh NJ, Greenstein A. Sildenafil versus the vacuum erection device: patient preference. Br J Urol. 2001;166(5):1779-1781.
Chen J, Wollman Y, Chernichovsky T, et al. Effect of oral administration of high-dose nitric oxide donor L-arginine in men with organic erectile dysfunction: results of a double-blind, randomized, placebo-controlled study. BJU Int. 1999;83(3):269-273. [pmid: 10233492].
Chen KC, Minor TX, Rahman NU, et al. The additive erectile recovery effect of brain-derived neurotrophic factor combined with vascular endothelial growth factor in a rat model of neurogenic impotence. BJU Int. 2005;95(7):1077-1080. [pmid: 15839936].
Chen KK, Jiann BP, Lin JSN, et al. Erratum: Efficacy and safety of on- demand oral tadalafil in the treatment of men eith erectile dysfunction in Taiwan: A randomized, double- blind, parallel, placebo- conrolled clinical study (Journal of Sexual Medicine vol. 1 (2)). Br J Sex Med. 2005;2(1):158.
Cheng JYW, Ng EML, Chen RYL, et al. Prevalence of erectile dysfunction in Asian populations: A meta-analysis. Int J Impot Res. 2007;19(3):229-244. [pmid: 16929338].
Chew KK. Prevalence of hypogonadism in the aging male and male erectile dysfunction in Asia-Pacific countries. Asian J Androl. 2003;5(2):171-172.
Chew KK, Stuckey BG. Clinical course of penile fibrosis in intracavernosal prostaglandin E1 injection therapy: a follow-up of 44 patients. Int J Impot Res. 2003;15(2):94-98. [pmid: 12789387].
Chew KK, Stuckey BGA. Use of transurethral alprostadil (MUSE) (prostaglandin E1) for glans tumescence in a patient with penile prosthesis. Int J Impot Res. 2000;12(3):195-196. [pmid: 11045915].
Chew KK, Stuckey BGA, Thompson PL. Erectile dysfunction, sildenafil and cardiovascular risk. Med J Aust. 2000;172(6):279-283. [pmid: 10860094].
Chia S. Management of premature ejaculation—a comparison of treatment outcome in patients with and without erectile dysfunction. Int J Androl. 2002;25(5):301-305. [pmid: 12270028].
Chinegwundoh F, Anie K A. Treatments for priapism in boys and men with sickle cell disease. [Review][16 refs]. Cochrane Database Syst Rev 2004;(4):CD004198
Chiu KC, Cohan P, Martinez D, et al. Adrenal insufficiency after medical therapy for prolactin and adrenocorticotropic hormone co-producing pituitary macroadenoma without hypercortisolism. Endocr Pract. 2001;11(6):443-446.
Chiu YJ, Reid IA. Effect of sildenafil on renin secretion in human subjects. Experimental biology and medicine (Maywood, NJ). 2002;227(8):620-625.
Christ B, Brockmeier D, Hauck EW, et al. Interactions of sildenafil and tacrolimus in men with erectile dysfunction after kidney transplantation. Urology. 2001;58(4):589-593. [pmid: 11597545].
Christ GJ, Melman A. The application of gene therapy to the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):111-112. [pmid: 9647947].
Chue P. Gabapentin treatment for premature ejaculation [3]. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 2004;49(9):644-645. [pmid: 15503740].
Cimentepe E, Unsal A, Saglam R. Randomized clinical trial comparing transurethral needle ablation with transurethral resection of the prostate for the treatment of benign prostatic hyperplasia: results at 18 months. J Endourol. 2003;17(2):103-107. [pmid: 12689404].
Clark C. Erectile dysfunction and other problems. Can Pharm J. 2004;272(7299):608-610.
Clark RV, Hermann DJ, Cunningham GR, et al. Marked Suppression of Dihydrotestosterone in Men with Benign Prostatic Hyperplasia by Dutasteride, a Dual 5a-Reductase Inhibitor. Journal of Clinical Endocrinology & Metabolism. 2004;89(5):2179-2184. [pmid: 15126539].
Claro JA, Passerotti CC, Figueiredo Neto AC, et al. An alternative non-invasive treatment for Peyronie's disease. International Braz J Urol. 2004;30(3):199-204. [pmid: 15689246].
Clough J. CNS-targeted sexual dysfunction drug for men and women. Drug Discov Today. 2002;7(9):492-494. [pmid: 11983559].
Coelho OR. Tolerability and safety profile of sildenafil citrate (Viagra) in Latin American patient populations. Int J Impot Res. 2002;14(Suppl 2):54-59. [pmid: 11896479].
Coker C, Bettocchi C, Pryor J. Caverject, a new licensed prostaglandin preparation for use in erectile dysfunction. J Androl. 1994;15(6 SUPPL.):71S.
Coleman CI, Carabino JM, Vergara CM, et al. Vardenafil. Hosp Formul. 2003;38(3):131-148.
Collazos J, Martinez E, Mayo J, et al. Sexual dysfunction in HIV-infected patients treated with highly active antiretroviral therapy. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2002;31(3):322-326. [pmid: 12439208].
Colp GM, Scroppo FI. Can self-directed pelvic floor exercises improve erectile function?. Nature Clinical Practice Urology. 2005;2(3):128-129.
Conti CR, Pepine CJ, Sweeney M. Efficacy and safety of sildenafil citrate in the treatment of erectile dysfunction in patients with ischemic heart disease. Am J Cardiol. 1999;83(5A):29C-34C.
Contreras LN, Masini AM, Danna MM, et al. Glucocorticoids: their role on gonadal function and LH secretion. Minerva Endocrinol. 1996;21(2):43-46. [pmid: 8968148].
Cooper AJ, Losztyn S, Russell NC, et al. Medroxyprogesterone acetate, nocturnal penile tumescence, laboratory arousal, and sexual acting out in a male with schizophrenia. Arch Sex Behav. 1990;19(4):361-372. [pmid: 2144727].
Cormio L, Nisen H, Ruutu M, et al. Etilefrine in the prevention of prolonged erection after diagnostic pharmacological stimulation. Ann Chir Gynaecol. 1996;85(3):247-250. [pmid: 8950448].
Corona G, Mannucci E, Fisher AD, et al. Effect of hyperprolactinemia in male patients consulting for sexual dysfunction. Br J Sex Med. 2007;4(5):1485-1493.
Corona G, Mannucci E, Petrone L, et al. ANDROTEST: a structured interview for the screening of hypogonadism in patients with sexual dysfunction. Br J Sex Med. 2006;3(4):706-715.
Corona G, Mannucci E, Petrone L, et al. Association of hypogonadism and type II diabetes in men attending an outpatient erectile dysfunction clinic. Int J Impot Res. 2006;18(2):190-197. [pmid: 16136189].
Corona G, Mannucci E, Schulman C, et al. Psychobiologic correlates of the metabolic syndrome and associated sexual dysfunction. Eur Urol. 2006;50(3):595-604. [pmid: 16564129].
Creasey GH. Lecture 6: restoration of male sexual function following spinal cord injury. Int J Impot Res. 2000;12(Suppl 3):S54-S55. [pmid: 11002403].
Crowe SM, Streetman DS. Vardenafil treatment for erectile dysfunction. [Review] [43 refs]. Ann Pharmacother. 2004;38(1):77-85. [pmid: 14742800].
Crum-Cianflone NF, Bavaro M, Hale B, et al. Erectile dysfunction and hypogonadism among men with HIV. AIDS Patient Care & Stds. 2007;21(1):9-19. [pmid: 17263654].
Culha M, Mutlu N, Acar O, et al. Patient-partner satisfaction with intracavernous medication supported with oral agents in selected cases of Peyronie's disease: A ten-month follow-up study. International Urology & Nephrology. 1999;31(2):257-262. [pmid: 10481972].
Curran M, Keating G. Tadalafil.[erratum appears in Drugs. 2003;63(23):2703]. [Review] [31 refs]. Drugs. 2003;63(20):2203-2212. [pmid: 14498756].
Curri SB, Menchini Fabris F. Evidence and results obtained with a new Trans-Epidermal Barrier (T.E.B.) drug in the medical treatment of vascular impotence. Boll Chim Farm. 1996;135(5):316-334. [pmid: 8942060].
Cyranoski D. Malaysian researchers bet big on home-grown Viagra. Nat Med. 2005;11(9):912. [pmid: 16145563].
Czuriga I, Riecansky I, Bodnar J, et al. Comparison of the New Cardioselective Beta-Blocker Nebivolol with Bisoprolol in Hypertension: The Nebivolol, Bisoprolol Multicenter Study (NEBIS). Cardiovascular Drugs & Therapy. 2003;17(3):257-263. [pmid: 14574084].
Dang G, Matern R, Bivalacqua TJ, et al. Intralesional interferon-alpha-2B injections for the treatment of Peyronie's disease. South Med J. 2004;97(1):42-46. [pmid: 14746421].
Davis BE, Weigel JW, Whitford CS. Treatment of male impotence: a new option. Kans Med. 1990;91(12):325-326. [pmid: 1705298].
Davis JM. American College of Neuropsychopharmacology - 43rd annual meeting. 12–16 December 2004, San Juan, Puerto Rico. IDrugs. 2005;8(2):100-103. [pmid: 15696406].
Davis ME, Brewster ME. Cyclodextrin-based pharmaceutics: Past, present and future. Nat Rev Genet. 2004;3(12):1023-1035.
De Meyer JM, Oosterlinck W. Influence of the method of intracavernous injection on penile rigidity: a possible pharmacokinetic explanation. Urology. 1997;49(2):248-252. [pmid: 9037289].
De Tejada I. Vardenafil Duration of Action. Eur Urol. 2006;50(5):901-902. [pmid: 16949729].
De Tejada I, Garvey DS, Schroeder JD, et al. Design and evaluation of nitrosylated alpha-adrenergic receptor antagonists as potential agents for the treatment of impotence. Journal of Pharmacology & Experimental Therapeutics. 1999;290(1):121-128. [pmid: 10381767].
Degirmenci B, Acar M, Albayrak R, et al. Effects of sildenafil citrate (Viagra) on renal arteries: An evaluation with Doppler ultrasound. Urol Int. 2006;77(2):170-172. [pmid: 16888425].
Del Popolo G, Li Marzi V, Mondaini N, et al. Time/duration effectiveness of sildenafil versus tadalafil in the treatment of erectile dysfunction in male spinal cord-injured patients. Proc Annu Clin Spinal Cord Inj Conf. 2004;42(11):643-648.
Delizonna LL, Wincze JP, Litz BT, et al. A comparison of subjective and physiological measures of mechanically produced and erotically produced erections (or, is an erection an erection?). J Sex Marital Ther. 2001;27(1):21-31. [pmid: 11224951].
Denisov MF, Davis JM, Brecher M. Re: Prolactin levels and adverse events in patients treated with risperidone [8] (multiple letters). J Clin Psychopharmacol. 2002;22(5):538-540. [pmid: 12352286].
Derby CA, Araujo AB, Johannes CB, et al. Measurement of erectile dysfunction in population-based studies: the use of a single question self-assessment in the Massachusetts Male Aging Study. Int J Impot Res. 2000;12(4):197-204. [pmid: 11079360].
Derby CA, Barbour MM, Hume AL, et al. Drug therapy and prevalence of erectile dysfunction in the Massachusetts Male Aging Study cohort. Pharmacotherapy. 2001;21(6):676-683. [pmid: 11401181].
Derouet H, Nolden W, Jost WH, et al. Treatment of erectile dysfunction by an external ischiocavernous muscle stimulator. Eur Urol. 1998;34(4):355-359. [pmid: 9748685].
Desouza C, Parulkar A, Lumpkin D, et al. Acute and prolonged effects of sildenafil on brachial artery flow-mediated dilatation in type 2 diabetes. Diabetes Care. 2002;25(8):1336-1339. [pmid: 12145231].
Dietzen CJ, Lloyd LK. Complications of intracavernous injections and penile prostheses in spinal cord injured men. Archives of Physical Medicine & Rehabilitation. 1992;73(7):652-655. [pmid: 1622321].
Dinelli N, Salinitri G, Pomara G, et al. Role of pharmacologic rehabilitation in the recovery of sexual function following radical prostatectomy. Minerva Urol Nefrol. 2005;57(4):325-329. [pmid: 16247354].
Dinsmore WW. Medical treatment of impotence with papaverine and phentolamine intracavernosal injection. Ulster Med J. 1990;59(2):174-176. [pmid: 2278115].
Dinsmore WW, Gingell C, Hackett G, et al. Treating men with predominantly nonpsychogenic erectile dysfunction with intracavernosal vasoactive intestinal polypeptide and phentolamine mesylate in a novel auto-injector system: a multicentre double-blind placebo-controlled study. BJU Int. 1999;83(3):274-279. [pmid: 10233493].
Djavan B, Milani S, Fong YK. Dutasteride: A novel dual inhibitor of 5a-reductase for benign prostatic hyperplasia. Expert Opin Pharmacother. 2005;6(2):311-317. [pmid: 15757426].
Doggrell SA. Comparison of clinical trials with sildenafil, vardenafil and tadalafil in erectile dysfunction. Expert Opin Pharmacother. 2005;6(1):75-84. [pmid: 15709885].
Donatucci CF, Lue TF. Erectile dysfunction in men under 40: etiology and treatment choice. Int J Impot Res. 1993;5(2):97-103. [pmid: 8348217].
Doumas M, Tsakiris A, Douma S, et al. Beneficial effects of switching from beta-blockers to nebivolol on the erectile function of hypertensive patients. Asian J Androl. 2006;8(2):177-182. [pmid: 16491268].
Dundar SO. Visual loss associated with erectile dysfunction drugs. Can J Ophthalmol. 2007;42(1):10-12. [pmid: 17361234].
Dupont Simon. Multiple sclerosis and sexual functioning: A review. Clin Rehabil. 1995;9(2):135-141.
Durackova Z, Trebaticky B, Novotny V, et al. Lipid metabolism and erectile function improvement by Pycnogenol, extract from the bark of Pinus pinaster in patients suffering from erectile dysfunction - A pilot study. Adv Food Nutr Res. 2003;23(9):1189-1198.
Eandi J A, Yao A P, Javidan J. Penile paraffinoma: the delayed presentation. Int Urol Nephrol 2007;
Eardley I. New oral therapies for the treatment of erectile dysfunction. Br J Urol. 1998;81(1):122-127. [pmid: 9467488].
Earle CM, Keogh EJ, Ker JK, et al. The role of intracavernosal vasoactive agents to overcome impotence due to spinal cord injury. Paraplegia. 1992;30(4):273-276. [pmid: 1625897].
Earle CM, Stuckey BG, Ching HL, et al. The incidence and management of priapism in Western Australia: a 16 year audit. Int J Impot Res. 2003;15(4):272-276. [pmid: 12934055].
Edwards G, Muirhead GJ. British Journal of Clinical Pharmacology: Introduction. Br J Clin Pharmacol. 2002;53(SUPPL. 1):1S-3S.
Ekmekcioglu O, Inci M, Demirci D, et al. Effects of sildenafil citrate on ejaculation latency, detumescence time, and refractory period: placebo-controlled, double-blind, crossover laboratory setting study. Urology. 2005;65(2):347-352. [pmid: 15708051].
Ekselius L, Von Knorring L. Effect on sexual function of long-term treatment with selective serotonin reuptake inhibitors in depressed patients treated in primary care. J Clin Psychopharmacol. 2001;21(2):154-160. [pmid: 11270911].
El Malik EMA. Erectile dysfunction: An update of diagnosis and management. Qatar Medical Journal. 2000;9(2):9-17.
El-Bahnasawy MS, El-Assmy A, Dawood A, et al. Effect of the use of internal iliac artery for renal transplantation on penile vascularity and erectile function: A prospective study. Br J Urol. 2004;172(6 I):2335-2339.
El-Rufaie Omer EF, Bener Abdulbari, Abuzeid Mohamed SO, et al. Sexual dysfunction among type II diabetic men: A controlled study. J Psychosom Res. 1997;43(6):605-612. [pmid: 9430073].
El-Sakka AI. Penile axial rigidity and Doppler ultrasonography parameters in patients with erectile dysfunction: association with type 2 diabetes. Urology. 2003;62(3):525-531. [pmid: 12946761].
Emilien G. Alprox-TD NexMed Inc. Current Opinion in Central & Peripheral Nervous System Investigational Drugs 2000;2(3):311–320.
Ende AR, Lo Re V, DiNubile MJ, et al. Erectile dysfunction in an urban HIV-positive population. AIDS Patient Care & Stds. 2006;20(2):75-78. [pmid: 16475887].
Engelhardt PF, Daha LK, Zils T, et al. Acupuncture in the treatment of psychogenic erectile dysfunction: first results of a prospective randomized placebo-controlled study. Int J Impot Res. 2003;15(5):343-346. [pmid: 14562135].
Engelson ES, Pi-Sunyer FX, Kotler DP. Effects of megestrol acetate therapy on body composition and circulating testosterone concentrations in patients with AIDS. Int J STD AIDS. 1995;9(9):1107-1108.
Engl T, Beecken WD, Wolfram M, et al. Uropharmacology: Current and future strategies in the treatment of erectile dysfunction and benign prostate hyperplasia. International Journal of Clinical Pharmacology & Therapeutics. 2004;42(10):527-533. [pmid: 15516021].
English JC, King DHC, Foley JP. Penile shaft hypopigmentation: Lichen sclerosus occurring after the initiation of alprostadil intracavernous injections for erectile dysfunction. J Am Acad Dermatol. 1998;39(5 I):801-803. [pmid: 9810901].
Ensign C. First-line therapies for erectile dysfunction. [Review] [8 refs]. JAAPA. 2001;14(10):17-20. [pmid: 11715672].
Erdogru T, Kocak T, Serdaroglu P, et al. Evaluation and therapeutic approaches of voiding and erectile dysfunction in neurological Behcet's syndrome. Br J Urol. 1999;162(1):147-153.
Ernst E. Chinese herbal medicines for consumers in the West. Focus on Alternative & Complementary Therapies. 2005;10(2):94-97.
Ernst E, Pittler MH. Yohimbine for erectile dysfunction: a systematic review and meta-analysis of randomized clinical trials. J Urol. 1998;159(2):433-436. [pmid: 9649257].
Escobar-Jimenez F. [Efficacy and safety of sildenafil in men with type 2 diabetes mellitus and erectile dysfunction]. Med Clin (Barc). 2002;119(4):121-124. [pmid: 12106522].
Esposito K, Giugliano F, Martedi E, et al. High proportions of erectile dysfunction in men with the metabolic syndrome. Diabetes Care. 2005;28(5):1201-1203. [pmid: 15855589].
Evans MF. Viagra! Are we ready?. Can Fam Physician. 1998;44:2103-2105. [pmid: 9805164].
Fagan Peter J, Blum Lois H. Issues in the psychotherapeutic treatment of sexual dysfunction following radical retropubic prostatectomy. Rosen, Raymond C (Ed); Leiblum, Sandra R (Ed) 1995;(1995):400
Fagan TC, Buttler S, Marbury T, et al. Cardiovascular safety of sublingual apomorphine in patients on stable doses of oral antihypertensive agents and nitrates. Am J Cardiol. 2001;88(7):760-766. [pmid: 11589843].
Faiman C. Endocrine causes of impotence. Cleve Clin J Med. 1993;60(6):428-429. [pmid: 7507006].
Fazeli-Matin S, Montague DK, Angermeier KW, et al. Penile fracture after intracavernous injection therapy. Br J Urol. 1998;159(6):2094.
Fedele D, Coscelli C, Cucinotta D, et al. Management of erectile dysfunction in diabetic subjects: results from a survey of 400 diabetes centres in Italy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14(5):277-282.
Fedele D, Lamonica M, Bax G. Experience with sildenafil in diabetes. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):49-52.
Fekete F, Fabian E. [Effectiveness and adverse effects of sildenafil in erectile dysfunction]. Orv Hetil. 2000;141(3):115-118. [pmid: 10693332].
Feldman HA, Goldstein I, Hatzichristou DG, et al. Impotence and its medical and psychosocial correlates: results of the Massachusetts Male Aging Study. Br J Urol. 1994;151(1):54-61.
Feldman HA, Johannes CB, Derby CA, et al. Erectile dysfunction and coronary risk factors: prospective results from the Massachusetts male aging study. Prev Med. 2000;30(4):328-338. [pmid: 10731462].
Fink HA, Mac Donald R, Rutks IR, et al. Sildenafil for male erectile dysfunction: a systematic review and meta-analysis. Arch Intern Med. 2002;162(12):1349-1360. [pmid: 12076233].
Fink HA, MacDonald R, Rutks IR, et al. Trazodone for erectile dysfunction: a systematic review and meta-analysis. BJU Int. 2003;92(4):441-446. [pmid: 12930437].
Finkbeiner A. Random musing about a little blue pill. J Ark Med Soc. 1998;95(3):100-101. [pmid: 9735630].
Fishbain David A. Impact of sildenafil on male erectile disorder due to psychological factors. Can J Psychiatry. 2000;45(1):85-86. [pmid: 10696497].
Fisher WA, Rosen RC, Eardley I, et al. The Multinational Men's Attitudes to Life Events and Sexuality (MALES) Study Phase II: Understanding PDE5 inhibitor treatment seeking patterns, among men with erectile dysfunction. Br J Sex Med. 2004;1(2):150-160.
Flack JM. The effect of doxazosin on sexual function in patients with benign prostatic hyperplasia, hypertension, or both.[see comment]. [Review] [47 refs]. Int J Clin Pract. 2002;56(7):527-530. [pmid: 12296615].
Foresta C, Caretta N, Rossato M, et al. Role of androgens in erectile function. Br J Urol. 2004;171(6 Pt 1):2358-2362.
Foulks CJ, Cushner HM. Sexual dysfunction in the male dialysis patient: pathogenesis, evaluation, and therapy. [Review] [105 refs]. Am J Kidney Dis. 1986;8(4):211-222. [pmid: 3532769].
Frank T. Tadalafil (Cialis-Lilly). Consultant Pharmacist. 2004;19(4):280-281.
Frank T. Vardenafil (Levitra-Bayer) GSK. Consultant Pharmacist. 2004;19(4):278-280.
Franzen D, Metha A, Seifert N, et al. Effects of beta-blockers on sexual performance in men with coronary heart disease. A prospective, randomized and double blinded study. Int J Impot Res. 2001;13(6):348-351. [pmid: 11918251].
Fraunfelder F W, Fraunfelder F T. Scientific Challenges in Postmarketing Surveillance of Ocular Adverse Drug Reactions. Am J Ophthalmol 2007;143(1):
Freemantle N. Valuing the effects of sildenafil in erectile dysfunction. Br Med J. 2000;320(7243):1156-1157. [pmid: 10784525].
Freytag SO, Stricker H, Pegg J, et al. Phase I Study of Replication-Competent Adenovirus-Mediated Double-Suicide Gene Therapy in Combination with Conventional-Dose Three-Dimensional Conformal Radiation Therapy for the Treatment of Newly Diagnosed, Intermediate- to High-Risk Prostate Cancer. Cancer Res. 2003;63(21):7497-7506. [pmid: 14612551].
Fu Q, Yao DH, Jiang YQ. Effect of sodium nitroprusside on hemodynamics of corpus cavernosum in Chinese. Asian J Androl. 2001;3(4):311-313. [pmid: 11753478].
Fugl-Meyer AR, Lodnert G, Branholm IB, et al. On life satisfaction in male erectile dysfunction. Int J Impot Res. 1997;9(3):141-148. [pmid: 9315491].
Fulgram PF, Cochran JS, Denman JL, et al. Re: Disappointing initial results with transurethral alprostadil for erectile dysfunction in a urology practice setting [5]. Br J Urol. 1999;162(4):1390.
Gallo L, Perdona S, Autorino R, et al. Recovery of erection after pelvic urologic surgery: our experience. Int J Impot Res. 2005;17(6):484-493. [pmid: 15889123].
Gerstenbluth RE, Maniam PN, Corty EW, et al. Prostate-specific antigen changes in hypogonadal men treated with testosterone replacement. J Androl. 2002;23(6):922-926. [pmid: 12399540].
Ghezzi A, Malvestiti GM, Baldini S, et al. Erectile impotence in multiple sclerosis: A neurophysiological study. J Neurol. 1995;242(3):123-126. [pmid: 7751853].
Giammusso B, Gattuso U, Vanaclocha V, et al. Percutaneous lumbar sympathectomy in the treatment of erectile dysfunction secondary to cavernous adrenergic hypertone: initial results of an original technique. Arch Ital Urol Androl. 2005;77(1):5-9. [pmid: 15906781].
Giampietro O, Ferdeghini M, Cerri M, et al. Evaluation of the hypothalamic-pituitary-testicular interaction in diabetic males. European J Lab Med. 1994;2(2):83-89.
Gillies HC, Roblin D, Jackson G. Coronary and systemic hemodynamic effects of sildenafil citrate: From basic science to clinical studies in patients with cardiovascular disease. Int J Cardiol. 2002;86(23):131-141. [pmid: 12419549].
Ginsberg DL. Gabapentin treatment of premature ejaculation. Primary Psychiatry. 2004;11(12):20-21.
Ginsberg DL. Vardenafil treatment of sertraline-induced sexual dysfunction. Primary Psychiatry. 2004;11(11):23-24.
Ginsberg David L. Sildenafil-dihydrocodeine interaction results in prolonged erections. [References]. Primary Psychiatry. 2003;10(2):23.
Ginzburg R, Wong Y, Fader JS. Effect of bupropion on sexual dysfunction. Ann Pharmacother. 2005;39(12):2096-2099. [pmid: 16288071].
Giuberti A, Picozzi SC, Mazza L, et al. Testosterone supplementation in hypogonadal men: our personal experience. Arch Ital Urol Androl. 2005;77(4):191-193. [pmid: 16444930].
Giuliano F. Control of penile erection by the melanocortinergic system: Experimental evidences and therapeutic perspectives. J Androl. 2004;25(5):683-691. [pmid: 15292097].
Giuliano F, Allard J, Rampin O, et al. Pro-erectile effect of systemic apomorphine: Existence of a spinal site of action. Br J Urol. 2002;167(1):402-406.
Giuliano F, Hultling C, El Masry WS, et al. Randomized trial of sildenafil for the treatment of erectile dysfunction in spinal cord injury. Sildenafil Study Group. Ann Neurol. 1999;46(1):15-21. [pmid: 10401776].
Giuliano F, Pena BM, Mishra A, et al. Efficacy results and quality-of-life measures in men receiving sildenafil citrate for the treatment of erectile dysfunction. Qual Life Res. 2001;10(4):359-369. [pmid: 11763248].
Giuliano Francois, Pena Beatrice, Mishra Avanish, et al. “Efficacy results and quality-of-life measures in men receiving sildenafil citrate for the treatment of erectile dysfunction”: Erratum. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care & Rehabilitation. 2002;11(6):613-670.
Gladh YM, Rahgozar M, Hammar ML, et al. Prevalence of symptoms possibly related to PADAM, in a Swedish population aged 55, 65 and 75 years. Maturitas. 2005;50(3):161-166. [pmid: 15734596].
Glasser SP. Revisiting erectile dysfunction in cardiovascular patients. Cardiology Review. 2003;20(12):42-43.
Glasser SP. Safety of PDE 5 inhibition in patients with cardiovascular disease. Cardiology Review. 2002;19(11):32-33.
Glenn DRJ, McClure N, Lewis SEM. The hidden impact of diabetes on male sexual dysfunction and fertility. Hum Fertil. 2003;6(4):174-179.
Goldenberg MM. Safety and efficacy of sildenafil citrate in the treatment of male erectile dysfunction. Clin Ther. 1998;20(6):1033-1048. [pmid: 9916601].
Goldstein I. Oral phentolamine: an alpha-1, alpha-2 adrenergic antagonist for the treatment of erectile dysfunction. [Review][9 refs]. Int J Impot Res 2000;12Suppl-80.
Gontero P, Fontana F, Zitella A, et al. A prospective evaluation of efficacy and compliance with a multistep treatment approach for erectile dysfunction in patients after non-nerve sparing radical prostatectomy. BJU Int. 2005;95(3):359-365. [pmid: 15679794].
Gore JL, Swerdloff RS, Rajfer J. Androgen deficiency in the etiology and treatment of erectile dysfunction. Urol Clin North Am. 2005;32(4):457-468. [pmid: 16291037].
Govier FE, McClure RD, Kramer-Levien D. Endocrine screening for sexual dysfunction using free testosterone determinations. Br J Urol. 1996;156(2 Pt 1):405-408.
Graul A, Castaner J. Phentolamine Mesilate. Treatment of erectile dysfunction. Drugs of the Future. 1998;23(7):725-728.
Graul AI. Latest findings on the diagnosis and treatment of erectile dysfunction. Drug News Perspect. 1996;9(9):572-575.
Gray PB, Singh AB, Woodhouse LJ, et al. Dose-dependent effects of testosterone on sexual function, mood, and visuospatial cognition in older men. Journal of Clinical Endocrinology & Metabolism. 2005;90(7):3838-3846. [pmid: 15827094].
Greco E, Balbi PP, Virag R. Self intra-cavernous injections as a successful treatment in pure neurogenic impotence. Riv Neurol. 1991;61(1):35-38. [pmid: 1857921].
Green HJ, Pakenham KI, Headley BC, et al. Coping and health-related quality of life in men with prostate cancer randomly assigned to hormonal medication or close monitoring. Psychooncology. 2002;11(5):401-414. [pmid: 12228873].
Green JSA, Holden STR, Ingram P, et al. An investigation of erectile dysfunction in Gwent, Wales. BJU Int. 2001;88(6):551-553. [pmid: 11678749].
Greenstein A, Plymate SR, Katz PG. Visually stimulated erection in castrated men. Br J Urol. 1995;153(3:Pt 1):t-2.
Gresser U, Gleiter CH. Erectile dysfunction: comparison of efficacy and side effects of the PDE-5 inhibitors sildenafil, vardenafil and tadalafil—review of the literature. [Review] [92 refs]. Eur J Med Res. 2002;7(10):435-446. [pmid: 12435622].
Gross AJ, Sauerwein DH, Kutzenberger J, et al. Penile prostheses in paraplegic men. Br J Urol. 1996;78(2):262-264. [pmid: 8813925].
Grover JK, Vats V, Ajeeta. Sildenafil (Viagra(TM)). Medico-Legal Update. 1998;3(12):67-78.
Grugni G, Carani C, Maestroni G, et al. Melatonin levels in psychogenic impotence. Hormone & Metabolic Research. 1994;26(9):440-441. [pmid: 7835831].
Grunwald JE, Jacob SS, Siu K, et al. Acute effects of sildenafil citrate (Viagra) on intraocular pressure in open-angle glaucoma. Am J Ophthalmol. 2001;132(6):872-874. [pmid: 11730651].
Gryglewska B, Grodzicki T. Betaxolol in elderly patients in primary care. New Medicine. 2003;6(4):108-111.
Guay AT, Sabharwal P, Varma S, et al. Delayed diagnosis of psychological erectile dysfunction because of the presence of macroprolactinemia. Journal of Clinical Endocrinology & Metabolism. 1996;81(7):2512-2514. [pmid: 8675569].
Guay DRP. Geriatric pharmacotherapy updates. American Journal Geriatric Pharmacotherapy. 2004;2(1):81-87.
Guirguis W R, Maytom M C, Orr M et al. SILDENAFIL FOR ERECTILE DYSFUNCTION - A ONE-YEAR STUDY. 151st Annual Meeting of the American Psychiatric Association 1998;Toronto, Ontario, Canada. 30th May–4th June. 1998. Issue No. 63, 1998.
Guo YL, Zhu JC, Pan TM, et al. Efficacy and safety of oral sildenafil in the treatment of erectile dysfunction. Chinese Journal of Urology. 2001;22(7):389-394.
Gupta N, Sawlani KK, Tripathi AK. Appropriate use of sildenafil citrate in male erectile dysfunction.[see comment]. [Review] [52 refs]. J Assoc Physicians India. 2001;49:889-896. [pmid: 11837756].
Gupta S, Salimpour P, de Saenz, et al. A possible mechanism for alteration of human erectile function by digoxin: inhibition of corpus cavernosum sodium/potassium adenosine triphosphatase activity. Br J Urol. 1998;159(5):1529-1536.
Hackett GI. The treatment of patients with diabetes. Int J STD AIDS. 1996;7(Suppl 3):24-26. [pmid: 8876378].
Haensel SM, Klem TM, Hop WC, et al. Fluoxetine and premature ejaculation: a double-blind, crossover, placebo-controlled study. J Clin Psychopharmacol. 1998;18(1):72-77. [pmid: 9472846].
Haensel SM, Rowland DL, Kallan KT. Clomipramine and sexual function in men with premature ejaculation and controls. Br J Urol. 1996;156(4):1310-1315.
Hamed S, Mohamed K, El-taher A, et al. The sexual and reproductive health in men with generalized epilepsy: A multidisciplinary evaluation. Int J Impot Res. 2006;18(3):287-295. [pmid: 16254569].
Hammadeh MY, Philp T. Transurethral electrovaporization of the prostate (TUVP) is effective, safe and durable. [Review] [28 refs]. Prostate Cancer & Prostatic Diseases. 2003;6(2):121-126. [pmid: 12806369].
Hammadeh MY, Madaan S, Hines J, et al. 5-year outcome of a prospective randomized trial to compare transurethral electrovaporization of the prostate and standard transurethral resection. Urology. 2003;61(6):1166-1171. [pmid: 12809891].
Hanash KA. Comparative results of goal oriented therapy for erectile dysfunction. Br J Urol. 1997;157(6):2135-2138.
Harman SM. Testosterone, Sexuality, and Erectile Function in Aging Men. J Androl. 2003;24(6 SUPPL.):S42-S45. [pmid: 14581494].
Hartmann Uwe, Langer Dieter. Combination of psychosexual therapy and intrapenile injections in the treatment of erectile dysfunctions: Rationale and predictors of outcome. J Sex Educ Ther. 1993;19(1):1-12.
Harwood PJ, Grotz M, Eardley I, et al. Erectile dysfunction after fracture of the pelvis. Journal of Bone & Joint Surgery - British Volume. 2005;87(3):281-290.
Haslam MT. A trial of idazoxan and yohimbine in erectile dysfunction. Sex Marital Ther. 1992;7(3):261-266.
Hatzichristou D G. Sildenafil citrate: lessons learned from 3 years of clinical experience. [Review][60 refs]. Int J Impot Res 2002;14Suppl-52.
Hatzichristou D G. Current treatment and future perspectives for erectile dysfunction. [Review][85 refs]. Int J Impot Res 1998;10Suppl-13.
Hatzimouratidis K, Hatzichristou D. Testosterone and erectile function: an unresolved enigma. Eur Urol. 2007;52(1):26-28. [pmid: 17379397].
Hatzimouratidis K, Hatzichristou D. Phosphodiesterase Type 5 Inhibitors: The Day After. Eur Urol. 2007;51(1):75-89. [pmid: 16949200].
Hatzimouratidis K, Hatzichristou DG. A comparative review of the options for treatment of erectile dysfunction: Which treatment for which patient?. Drugs. 2005;65(12):1621-1650. [pmid: 16060698].
Hawton Keith, Catalan Jose, Fagg Joan. Sex therapy for erectile dysfunction: Characteristics of couples, treatment outcome, and prognostic factors. Arch Sex Behav. 1992;21(2):161-175. [pmid: 1580787].
Hazell P. Review of new compounds available in Australia for the treatment of attention-deficit hyperactivity disorder. Australasian Psychiatry. 2004;12(4):369-375. [pmid: 15715810].
He XQ, Hong BF, Wang XX, et al. Evaluation of efficacy and safety of oral sildenafil citrate therapy for men with erectile dysfunction. Pharmaceutical Journal of Chinese Peoples Liberation Army. 2002;18(4):205-208.
Heaton J. New classification system for erectile dysfunction therapies. J Androl. 1998;19(4):399-404. [pmid: 9733141].
Heaton JP. Key issues from the clinical trials of apomorphine SL. World J Urol. 2001;19(1):25-31. [pmid: 11289567].
Heaton JPW, Altwein JE. The role of apomorphine SL in the treatment of male erectile dysfunction. BJU International - Supplement. 2001;88(3):36-38.
Heaton JPW, Wagner Porst, Eid Wyllie. Apomorphine: An update of clinical trial results. Int J Impot Res. 2000;12(SUPPL. 4):S67-S73. [pmid: 11035390].
Heaton JP, Dean J, Sleep DJ. Sequential administration enhances the effect of apomorphine SL in men with erectile dysfunction. Int J Impot Res. 2002;14(1):61-64. [pmid: 11896482].
Hellstrom WJG, Kendirci M. Type 5 Phosphodiesterase Inhibitors: Curing Erectile Dysfunction. Eur Urol. 2006;49(6):942-945. [pmid: 16563607].
Hellstrom WJ, Overstreet JW, Yu A, et al. Tadalafil has no detrimental effect on human spermatogenesis or reproductive hormones.[see comment]. Br J Urol. 2003;170(3):887-891.
Hellstrom Wayne JG, Egan Robert A, McGee Hall T, et al. “Visual field defect and intracerebral hemorrhage associated with use of vardenafil (Levitra)”: Comment and Reply. [References]. Neurology. 2006;66(2):293-294. [pmid: 16434684].
Herrmann HC, Chang G, Klugherz BD, et al. Hemodynamic effects of sildenafil in men with severe coronary artery disease.[see comment]. N Engl J Med. 2000;342(22):1622-1626. [pmid: 10833207].
Hirshkowitz M, Moore CA, O'Connor S, et al. Androgen and sleep-related erections. J Psychosom Res. 1997;42(6):541-546. [pmid: 9226601].
Hirst JF, Watson JP. Referrals aged 60+ to an inner-city psychosexual dysfunction clinic. Sexual & Marital Therapy. 1996;11(2):131-146.
Hofner K, Claes H, De Reijke TM, et al. Tamsulosin 0.4 mg once daily: effect on sexual function in patients with lower urinary tract symptoms suggestive of benign prostatic obstruction. Eur Urol. 1999;36(4):335-341. [pmid: 10473995].
Hollander JB, Gonzalez J, Norman T. Patient satisfaction with pharmacologic erection program. Urology. 1992;39(5):439-441. [pmid: 1580034].
Holt S. Natural approaches to promote sexual function: Part 1: Viagra versus a natural approach. Alternative & Complementary Therapies. 1999;5(4):204-208.
Holtkamp M, Weissinger F, Meierkord H. Erectile dysfunction with topiramate. Epilepsia. 2005;46(1):166-167. [pmid: 15660786].
Hong B, Ji YH, Hong JH, et al. A double-blind crossover study evaluating the efficacy of korean red ginseng in patients with erectile dysfunction: a preliminary report.[see comment]. Br J Urol. 2002;168(5):2070-2073.
Hopps CV, Mulhall JP. Novel agents for sexual dysfunction. BJU Int. 2003;92(6):534-538. [pmid: 14511028].
Horita H, Sato Y, Adachi H, et al. Effects of levodopa on nocturnal penile tumescence: a preliminary study. J Androl. 1998;19(5):619-624. [pmid: 9796623].
Howes OD, Wheeler MJ, Pilowsky LS, et al. Sexual function and gonadal hormones in patients taking antipsychotic treatment for schizophrenia or schizoaffective disorder. Hillside J Clin Psychiatry. 2007;68(3):361-367.
Howes Oliver D, Smith Shubulade, Aitchison Kathy JE. Comments on “Prolactin Levels and Erectile Function in Patients Treated With Risperidone.” [References]. J Clin Psychopharmacol. 2005;25(4):393-394. [pmid: 16012288].
Huang ST, Hsieh ML. Different hemodynamic responses by color Doppler ultrasonography studies between sildenafil non-responders and responders. Asian J Androl. 2007;9(1):129-133. [pmid: 17187164].
Huang WJ, Chen KK, Chang LS. Correlation between voiding and erectile function in patients with symptomatic benign prostatic hyperplasia. Journal of the Chinese Medical Association: JCMA. 2005;68(4):178-182. [pmid: 15850068].
Hubler J, Szanto A, Konyves K. Methylene blue as a means of treatment for priapism caused by intracavernous injection to combat erectile dysfunction. International Urology & Nephrology. 2003;35(4):519-521. [pmid: 15198160].
Hultling C. Partners' perceptions of the efficacy of sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Clin Pract 1999;Supplement.102–108.
Hummel S, Paisley S, Morgan A, et al. Clinical and cost-effectiveness of new and emerging technologies for early localised prostate cancer: A systematic review. Health Technol Assess. 2003;7(33):157p.
Hunter R H, Joy C B, Kennedy E et al. Risperidone versus typical antipsychotic medication for schizophrenia.[update of Cochrane Database Syst Rev. 2000;(2):CD000440; PMID: 10796543]. [Review][105 refs]. Cochrane Database Syst Rev 2003;(2):CD000440
Hyer SL, Duckworth K, Jones C. Managing erectile disorders in diabetes: The one stop andrology clinic. Practical Diabetes International. 1998;15(8):225-226.
Isidori AM, Giannetta E, Gianfrilli D, et al. Effects of testosterone on sexual function in men: results of a meta-analysis. Clin Endocrinol (Oxf). 2005;63(4):381-394. [pmid: 16181230].
Israilov S, Baniel J, Shmueli J, et al. Treatment program for erectile dysfunction in patients with cardiovascular diseases. Am J Cardiol. 2004;93(6):689-693. [pmid: 15019870].
Jackson G. Erectile dysfunction and cardiovascular disease.[see comment]. [Review] [46 refs]. Int J Clin Pract. 1999;53(5):363-368. [pmid: 10695101].
Jackson G. Treatment of erectile dysfunction in patients with cardiovascular disease: Guide to drug selection. Drugs. 2004;64(14):1533-1545. [pmid: 15233591].
Jackson G. Vardenafil - PDE5 inhibitor number 3. Int J Clin Pract. 2004;58(3):229. [pmid: 15117087].
Jackson G. PDE5 inhibitors: Looking beyond ED. Int J Clin Pract. 2003;57(3):159-160. [pmid: 12723713].
Jackson G. Sildenafil (Viagra): New data, new confidence in treating erectile dysfunction in the cardiovascular patient. Int J Clin Pract. 2002;56(2):75. [pmid: 11926708].
Jackson G. Phosphodiesterase 5 inhibition: Effects on the coronary vasculature. Int J Clin Pract. 2001;55(3):183-188. [pmid: 11351772].
Jackson G. The metabolic syndrome and erectile dysfunction: multiple vascular risk factors and hypogonadism. Eur Urol. 2006;50(3):426-427. [pmid: 16644094].
Jackson G, Montorsi P, Cheitlin MD. Cardiovascular safety of sildenafil citrate (Viagra): an updated perspective. [Review] [52 refs]. Urology. 2006;68(3 Suppl):47-60. [pmid: 17011375].
Jackson G, Sweeney M, Osterloh IH. Sildenafil citrate (Viagra(TM)): A cardiovascular overview. British Journal of Cardiology. 1999;6(6):325-334.
Jain P, Rademaker AW, McVary KT. Testosterone supplementation for erectile dysfunction: results of a meta-analysis. Br J Urol. 2000;164(2):371-375.
James J S. Frequent urination, leg cramps, leg weakness, erection difficulties: HIV myelopathy amino acid study. AIDS Treat News 2000;(344):3–4.
Jani AB. The effectiveness of combining hormone therapy and radiotherapy in the treatment of prostate cancer. Expert Opin Pharmacother. 2004;5(12):2469-2477. [pmid: 15571465].
Jani AB, Kao J, Heimann R, et al. Hormone therapy and radiotherapy for early prostate cancer: A utility-adjusted number needed to treat (NNT) analysis. Int J Radiat Oncol Biol Phys. 2005;61(3):687-694. [pmid: 15708246].
Jarow JP, Nana-Sinkam P, Sabbagh M, et al. Outcome analysis of goal directed therapy for impotence. Br J Urol. 1996;155(5):1609-1612.
Jeong SJ, Park K, Moon JD, et al. Bicycle saddle shape affects penile blood flow. Int J Impot Res. 2002;14(6):513-517. [pmid: 12494288].
Jiann BP, Yu CC, Su CC. Impact of introduction of sildenafil on other treatment modalities for erectile dysfunction: A study of nationwide and local hospital sales. Int J Impot Res. 2004;16(6):527-530. [pmid: 15229626].
Jordan GH. What's new in urology. J Am Coll Surg. 2003;197(3):444-457. [pmid: 12946801].
Kadioglu A, Erdogru T, Tellaloglu S. Evaluation of penile arteries in papaverine-induced erection with color Doppler ultrasonography. Arch Esp Urol. 1995;48(6):654-658. [pmid: 7661649].
Kamel HK, Morley JE. The management of erectile dysfunction. Reproductive Medicine Review. 2001;9(1):35-47.
Kang BJ, Lee SJ, Kim MD, et al. A placebo-controlled, double-blind trial of Ginkgo biloba for antidepressant-induced sexual dysfunction. Hum Psychopharmacol. 2002;17(6):279-284. [pmid: 12404672].
Kaplan SA, Meehan AG, Shah A. The age related decrease in testosterone is significantly exacerbated in obese men with the metabolic syndrome. What are the implications for the relatively high incidence of erectile dysfunction observed in these men?. Br J Urol. 2006;176(4 Pt 1):1524-1527.
Karlawish JH, Casarett D. Sildenafil for diabetic men with erectile dysfunction.[comment]. JAMA. 1999;282(10):940-941. [pmid: 10485673].
Kassouf W, Carrier S. A comparison of the International Index of Erectile Function and erectile dysfunction studies. BJU Int. 2003;91(7):667-669. [pmid: 12699481].
Kaufman JM, Hatzichristou DG, Mulhall JP, et al. Impotence and chronic renal failure: a study of the hemodynamic pathophysiology. Br J Urol. 1994;151(3):612-618.
Keijzers GB. Aviptadil (Senatek). [Review] [36 refs]. Curr Opin Investig Drugs. 2001;2(4):545-549.
Keles I, Aydin G, Orkun S, et al. Two clinical problems in elderly men: osteoporosis and erectile dysfunction. Arch Androl. 2005;51(3):177-184. [pmid: 16025856].
Kell P. Cardiovascular safety of sildenafil. Int J STD AIDS. 2002;13(7):439-443. [pmid: 12171661].
Keoghane SR, Sullivan ME, Miller MAW. The aetiology, pathogenesis and management of priapism. BJU Int. 2002;90(2):149-154. [pmid: 12081756].
Kerfoot WW, Park HY, Schwartz LB, et al. Characterization of calcium channel blocker induced smooth muscle relaxation using a model of isolated corpus cavernosum. Br J Urol. 1993;150(1):249-252.
Kernohan AF, McIntyre M, Hughes DM, et al. An oral yohimbine/L-arginine combination (NMI 861) for the treatment of male erectile dysfunction: a pharmacokinetic, pharmacodynamic and interaction study with intravenous nitroglycerine in healthy male subjects. Br J Clin Pharmacol. 2005;59(1):85-93. [pmid: 15606445].
Khalaf IM, Levinson IP. Erectile dysfunction in the Africa/Middle East Region: Epidemiology and experience with sildenafil citrate (Viagra). Int J Impot Res. 2003;15(SUPPL. 1):S1-S2. [pmid: 12825101].
Khan LA. Sildenafil citrate (Viagra). JK Pract. 2001;8(1):52-53.
Khan MA, Raistrick M, Mikhailidis DP, et al. MUSE: clinical experience. Current Medical Research & Opinion. 2002;18(2):64-67. [pmid: 12017211].
Kilic S, Ergin H, Baydinc YC. Venlafaxine extended release for the treatment of patients with premature ejaculation: a pilot, single-blind, placebo-controlled, fixed-dose crossover study on short-term administration of an antidepressant drug. Int J Androl. 2005;28(1):47-52. [pmid: 15679621].
Kilic S, Salih M, Anafarta K, et al. Adenosine: a new agent in the diagnosis of impotence. Int J Impot Res. 1994;6(4):191-198. [pmid: 7795719].
Kim JM, Joh YD, Huh JD, et al. Doppler sonography of the penile cavernosal artery: comparison of intraurethral instillation and intracorporeal injection of prostaglandin E1. J Clin Ultrasound. 2001;29(5):273-278. [pmid: 11486321].
Kim NN. Phosphodiesterase type 5 inhibitors: A biochemical and clinical correlation survey. Int J Impot Res. 2003;15(SUPPL. 5):S13-S19. [pmid: 14551572].
Kim NN, Dhir V, Azadzoi KM, et al. Pilot study of the endothelin-A receptor selective antagonist BMS-193884 for the treatment of erectile dysfunction. J Androl. 2001;23(1):76-83. [pmid: 11780926].
Kim SC, Seo KK, Lee SK, et al. Comparison of the synergistic effects of tamsulosin versus phentolamine on penile erection: In vitro and in vivo studies. Urol Res. 1999;27(6):437-444. [pmid: 10651132].
Kim SC, Seo KK, Park BD, et al. Risk factors for an early increase in dose of vasoactive agents for intracavernous pharmacotherapy. Urol Int. 2000;65(4):204-207. [pmid: 11112870].
Kimoto Y, Sakamoto S, Fujikawa K, et al. Up-titration of vardena fi l dose from 10 mg to 20 mg improved erectile function in men with spinal cord injury. Int J Urol. 2006;13(11):1428-1433. [pmid: 17083398].
Kirby RS. Report from London. Prostate Cancer & Prostatic Diseases. 2005;8(4):299. [pmid: 16319940].
Kirby RS, Andersen M, Gratzke P, et al. A combined analysis of double-blind trials of the efficacy and tolerability of doxazosin-gastrointestinal therapeutic system, doxazosin standard and placebo in patients with benign prostatic hyperplasia. BJU Int. 2001;87(3):192-200. [pmid: 11167641].
Kirby RS, O'Leary MP, Carson C. Efficacy of extended-release doxazosin and doxazosin standard in patients with concomitant benign prostatic hyperplasia and sexual dysfunction. BJU Int. 2005;95(1):103-109. [pmid: 15638905].
Kiriakova N, Kiriakov A, Schneider E, et al. Therapeutic effect of essential phospholipids on functional sexual disorders in males. Journal of the European Academy of Dermatology & Venereology. 1998;11(2):191-193. [pmid: 9784056].
Kleinberg DL, Davis JM, De Coster R, et al. Prolactin levels and adverse events in patients treated with risperidone.[see comment]. J Clin Psychopharmacol. 1999;19(1):57-61. [pmid: 9934944].
Kley HK, Stremmel W, Kley JB, et al. Testosterone treatment of men with idiopathic hemochromatosis. Clin Investig. 1992;70(7):566-572.
Kloner RA. Cardiovascular risk and sildenafil. [Review] [27 refs]. Am J Cardiol. 2000;86(2A):57F-61F.
Kloner RA, Zusman RM. Cardiovascular effects of sildenafil citrate and recommendations for its use. [Review] [21 refs]. Am J Cardiol. 1999;84(5B):11N-17N.
Kloner RA, Brindis RG, Cheitlin MD, et al. Roundtable discussion: Tadalafil study group. Am J Cardiol. 2003;92(9 SUPPL. 1):58M-65M.
Kloner RA, Hutter AM, Emmick JT, et al. Time course of the interaction between tadalafil and nitrates.[see comment]. J Am Coll Cardiol. 2003;42(10):1855-1860. [pmid: 14642699].
Kloner RA, Jackson G, Emmick JT, et al. Interaction between the phosphodiesterase 5 inhibitor, tadalafil and 2 alpha-blockers, doxazosin and tamsulosin in healthy normotensive men. Br J Urol. 2004;172(5:Pt 1):t-40.
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil in patients on common antihypertensive therapies. [Review] [5 refs]. Am J Cardiol. 2003;92(9A):47M-57M. [pmid: 12842244].
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil. [Review] [12 refs]. Am J Cardiol. 2003;92(9A):37M-46M.
Klotz T, Mathers MJ, Braun M, et al. Effectiveness of oral L-arginine in first-line treatment of erectile dysfunction in a controlled crossover study. Urol Int. 1999;63(4):220-223. [pmid: 10743698].
Knegtering R, Castelein S, Bous H, et al. A Randomized Open-Label Study of the Impact of Quetiapine Versus Risperidone on Sexual Functioning. J Clin Psychopharmacol. 2004;24(1):56-61. [pmid: 14709948].
Knispel HH. Penile venous surgery in impotence: results in highly selected cases. Urol Int. 1991;47(3):144-148. [pmid: 1771702].
Knoll LD, Benson RC, Bilhartz DL, et al. A randomized crossover study using yohimbine and isoxsuprine versus pentoxifylline in the management of vasculogenic impotence. Br J Urol. 1996;155(1):144-146.
Kobayashi T, Okuno H, Nishiyama H, et al. Adult-onset idiopathic hypogonadotropic hypogonadism presented with erectile and ejaculatory disorder. Int J Urol. 2002;9(10):604-606. [pmid: 12445243].
Kramer-Levien D J. Papaverine—the medical implant. AUAA J 1987;7(4):13-Jun.
Krause W, Mueller U, Mazur A. Measurement of steroid levels in saliva in a population-based survey of lifestyle, medical conditions, marriage, sex life and hormone status in aging men: A feasibility study. Aging Male. 2002;5(4):203-215. [pmid: 12630067].
Kriston L, Harms A, Berner MM. A meta-regression analysis of treatment effect modifiers in trials with flexible-dose oral sildenafil for erectile dysfunction in broad-spectrum populations. Int J Impot Res. 2006;18(6):559-565. [pmid: 16688210].
Kromann-Andersen B. Intracavernosal pharmacotherapy with injection pen. Lancet. 1988;1(85756):54-59. [pmid: 2891913].
Kuba R, Pohanka M, Zakopcan J, et al. Sexual dysfunctions and blood hormonal profile in men with focal epilepsy. Epilepsia. 2006;47(12):2135-2140. [pmid: 17201714].
Kukreja RC, Ockaili R, Salloum F, et al. Cardioprotection with phosphodiesterase-5 inhibition - A novel preconditioning strategy. Journal of Molecular & Cellular Cardiology. 2004;36(2):165-173. [pmid: 14871543].
Kunelius P, Hakkinen J, Lukkarinen O. Is high-dose yohimbine hydrochloride effective in the treatment of mixed-type impotence? A prospective, randomized, controlled double-blind crossover study. Urology. 1997;49(3):441-444. [pmid: 9123711].
Kupecz D. Alprostadil for the treatment of erectile dysfunction. J Am Acad Nurse Pract. 1996;21(5):143-145.
Kupelian V, Shabsigh R, Travison TG, et al. Is there a relationship between sex hormones and erectile dysfunction? Results from the Massachusetts Male Aging Study. Br J Urol. 2006;176(6 Pt 1):2584-2588.
Kvistborg A, Halse J, Bakke S, et al. Long-term treatment of macroprolactinomas with CV 205-502. Acta Endocrinol (Copenh). 1993;128(4):301-307. [pmid: 8098891].
La Pera G, Franco Giannotti C, Taggi F, et al. Prevalence of sexual disorders in those young males who later become drug abusers. J Sex Marital Ther. 2003;29(2):149-156. [pmid: 12623766].
La Vignera S, Calogero AE, Cannizzaro MA, et al. Erectile vascular dysfunction and analysis of the risk factors related to it. Clinical experience. Minerva Endocrinol. 2007;32(1):17-21. [pmid: 17353863].
Labbate Lawrence A. “Sex and serotonin reuptake inhibitor antidepressants”: Erratum. Psychiatr Ann. 1999;29(12):683.
Labbate Lawrence A, Croft Harry A, Oleshansky Marvin AE. Antidepressant-Related Erectile Dysfunction: Management via Avoidance, Switching Antidepressants, Antidotes, and Adaptation. [References]. Hillside J Clin Psychiatry. 2003;64(Suppl 10):11-19.
Labbate Lawrence A, Grimes Jamie, Hines Alan, et al. Sexual dysfunction induced by serotonin reuptake antidepressants. J Sex Marital Ther. 1998;24(1):3-12. [pmid: 9509375].
Lamberg L. New drug for erectile dysfunction boon for many, ‘viagravation’ for some. J Am Med Assoc. 1998;280(10):867-869.
Larson TR. Current treatment options for benign prostatic hyperplasia and their impact on sexual function. Urology. 2003;61(4):692-698. [pmid: 12670545].
Lasaponara F, Paradiso M, Milan MG, et al. Erectile dysfunction after kidney transplantation: our 22 years of experience.[see comment]. Transplant Proc. 2004;36(3):502-504. [pmid: 15110572].
Laties A, Sharlip I. Ocular safety in patients using sildenafil citrate therapy for erectile dysfunction. [Review] [81 refs]. Br J Sex Med. 2006;3(1):12-27.
Laties AM, Zrenner E. Viagra (sildenafil citrate) and ophthalmology. Progress in Retinal & Eye Research. 2002;21(5):485-506. [pmid: 12207947].
Laties A M, Fraunfelder F T, Flach A J et al. Ocular safety of Viagra, (sildenafil citrate). Trans Am Ophthalmol Soc 1999;97(pp 115–128):-128.
Latini DM, Penson DF, Lubeck DP, et al. Longitudinal differences in disease specific quality of life in men with erectile dysfunction: Results from the exploratory comprehensive evaluation of erectile dysfunction study. Br J Urol. 2003;169(4):1437-1442.
Laumann Edward O, West Suzanne, Glasser Dale, et al. Prevalence and Correlates of Erectile Dysfunction by Race and Ethnicity Among Men Aged 40 or Older in the United States: From the Male Attitudes Regarding Sexual Health Survey. [References]. Br J Sex Med. 2007;4(1):57-65.
Lawless C, Cree J. Oral medications in the management of erectile dysfunction. [Review] [15 refs]. J Am Board Fam Pract. 1998;11(4):307-314. [pmid: 9719353].
Lawless C, Force RW. Sildenafil for erectile dysfunction. J Fam Pract. 1998;47(2):97-98. [pmid: 9722794].
Lawrence IG, Price DE, Howlett TA, et al. Correcting impotence in the male dialysis patient: experience with testosterone replacement and vacuum tumescence therapy. Am J Kidney Dis. 1998;31(2):313-319. [pmid: 9469503].
Lea AP, Bryson HM, Balfour JA. Intracavernous alprostadil. A review of its pharmacodynamic and pharmacokinetic properties and therapeutic potential in erectile dysfunction. [Review] [123 refs]. Drugs Aging. 1996;8(1):56-74. [pmid: 8785470].
Lebret T, Herve JM, Gorny P, et al. Efficacy and safety of a novel combination of L-arginine glutamate and yohimbine hydrochloride: a new oral therapy for erectile dysfunction. Eur Urol. 2002;41(6):608-613. [pmid: 12074777].
Lee WR. The role of androgen deprivation therapy combined with prostate brachytherapy. [Review] [31 refs]. Urology. 2002;60(3:Suppl 1):Suppl-44.
Lehmann K, Casella R, Blochlinger A, et al. Reasons for discontinuing intracavernous injection therapy with prostaglandin E1 (alprostadil). Urology. 1999;53(2):397-400. [pmid: 9933062].
Lehmann K, John H, Kacl G, et al. Variable response to intracavernous prostaglandin E1 testing for erectile dysfunction. Urology. 1999;54(3):539-543. [pmid: 10475368].
Lenze EJ, Karp JF, Mulsant BH, et al. Somatic symptoms in late-life anxiety: Treatment issues. Journal of Geriatric Psychiatry & Neurology. 2005;18(2):89-96. [pmid: 15911937].
Lenzi A. The role of the medical andrologist in the assisted reproduction era. J Endocrinol Invest. 2003;26(3):268-273. [pmid: 12809180].
Leslie SJ, Atkins G, Oliver JJ, et al. No adverse hemodynamic interaction between sildenafil and red wine. Clinical Pharmacology & Therapeutics. 2004;76(4):365-370. [pmid: 15470336].
Levien T, Baker DE. Lepirudin and sildenafil citrate. Hosp Pharm. 1998;33(12):1524-1552.
Levine SB. A slightly different idea. Arch Sex Behav. 2005;34(1):38-39. [pmid: 16092025].
Levy MM. Benefits being missed [5]. Can Pharm J. 2005;274(7334):109.
Lewis RL, Sadovsky R, Eardley I, et al. The efficacy of tadalafil in clinical populations. Br J Sex Med. 2005;2(4):517-531.
Lexchin J. New drugs with novel therapeutic characteristics. Have they been subject to randomized controlled trials?. Can Fam Physician. 2002;48(SEPT.):1487-1492. [pmid: 12371307].
Li JY, Li XY, Li M, et al. Decline of serum levels of free testosterone in aging healthy Chinese men. Aging Male. 2005;8(34):203-206. [pmid: 16390747].
Licht MR. Use of oral sildenafil (Viagra) in the treatment of erectile dysfunction. [Review] [13 refs]. Compr Ther. 1999;25(2):90-94. [pmid: 10091013].
Lim PHC, Man KL, Foo CN, et al. Clinical efficacy and safety of sildenafil citrate (Viagra) in a multi-racial population in Singapore: A retrospective study of 1520 patients. Int J Urol. 2002;9(6):308-315. [pmid: 12110094].
Lim P H C, Moorthy P, Benton K G F. The clinical safety of Viagra. Ann N Y Acad Sci 2002;962(pp 378–388):-388.
Limoge JP, Olins E, Henderson D, et al. Minimally invasive therapies in the treatment of erectile dysfunction in anticoagulated cases: a study of satisfaction and safety. Br J Urol. 1996;155(4):1276-1279.
Lin CS, Xin ZC, Lin G, et al. Phosphodiesterases as therapeutic targets. Urology. 2003;61(4):685-691. [pmid: 12670544].
Lincoln TM. Cyclic GMP and phosphodiesterase 5 inhibitor therapies: What's on the horizon. Mol Pharmacol. 2004;66(1):11-13. [pmid: 15213291].
Lindsey I. What is the incidence of sexual dysfunction in males following rectal excision for benign and malignant diseases?. National Research Register 2000;2000.
Linet OI, Neff LL. Intracavernous prostaglandin E1 in erectile dysfunction. Clin Investig. 1994;72(2):139-149.
Linnebur SA. Pharmacotherapy update: What's new about old medications. Annals of Long Term Care. 2004;12(9):34-44.
Lipshultz LI. Injection therapy for erectile dysfunction. N Engl J Med. 1996;334(14):913-914. [pmid: 8596577].
Lipshultz LI, Kim ED. Treatment of erectile dysfunction in men with diabetes. J Am Med Assoc. 1999;281(5):465-466.
Llisterri JL, Lozano Vidal JV, Aznar Vicente J, et al. Sexual dysfunction in hypertensive patients treated with losartan. Am J Med Sci. 2001;321(5):336-341. [pmid: 11370797].
Long RL, Sherman LS, Lombardi TJ. A goal-oriented, cost-effective approach to the diagnosis and treatment of 24 male erectile dysfunction. [Review] [24 refs]. J Ky Med Assoc. 1995;93(11):500-508. [pmid: 8778212].
Loudon Julia B. Potential confusion between erectile dysfunction and premature ejaculation: An evaluation of men presenting with erectile difficulty at a sex therapy clinic. Sexual & Marital Therapy. 1998;13(4):397-403.
Lu J, SJ Fan J, Zhu J, et al. The prospective and randomized control study of Viagra combined with Andriol in the treatment of ED in the aging male. Chinese Journal of Andrology. 2003;17(3):194-196.
Lue TF. Erectile dysfunction. N Engl J Med. 2000;342(24):1802-1813. [pmid: 10853004].
Lue TF. Impotence after radical pelvic surgery: physiology and management. [Review] [56 refs]. Urol Int. 1991;46(3):259-265. [pmid: 1926639].
Lukkarinen O, Tonttila P, Hellstrom P, et al. Non-prosthetic surgery in the treatment of erectile dysfunction. A retrospective study of 45 impotent patients in the University of Oulu. Scandinavian Journal of Urology & Nephrology. 1998;32(1):42-46. [pmid: 9561573].
Lunenfeld B. Androgen therapy in the aging male. [Review] [110 refs]. World J Urol. 2003;21(5):292-305. [pmid: 14576959].
Maan Z, Arya M, Shergill I, et al. Peyronie's disease: An update of the medical management. Expert Opin Pharmacother. 2004;5(4):799-805. [pmid: 15102564].
Maas R, Schwedhelm E, Albsmeier J, et al. The pathophysiology of erectile dysfunction related to endothelial dysfunction and mediators of vascular function. Vasc Med. 2002;7(3):213-225. [pmid: 12553745].
Mahmud A, Hennessy M, Feely J. Effect of sildenafil on blood pressure and arterial wave reflection in treated hypertensive men. J Hum Hypertens. 2001;15(10):707-713. [pmid: 11607801].
Maier U, Koinig G. Andrological findings in young patients under long-term antidepressive therapy with clomipramine. Psychopharmacology (Berl). 1994;116(3):357-359. [pmid: 7892427].
Mak R, De Backer G, Kornitzer M, et al. Prevalence and correlates of erectile dysfunction in a population-based study in Belgium. Eur Urol. 2002;41(2):132-138. [pmid: 12074399].
Manasia P, Pomerol J, Ribe N, et al. Comparison of the efficacy and safety of 90 mg versus 20 mg fluoxetine in the treatment of premature ejaculation. Br J Urol. 2003;170(1):164-165.
Manecke RG, Mulhall JP. Medical treatment of erectile dysfunction. [Review] [69 refs]. Ann Med. 1999;31(6):388-398. [pmid: 10680853].
Manganiello V. International Journal of Impotence Research: Editorial commentary. Int J Impot Res. 2004;16(SUPPL. 1):S1-S3. [pmid: 15224126].
Mann K, Klingler T, Noe S, et al. Effects of yohimbine on sexual experiences and nocturnal penile tumescence and rigidity in erectile dysfunction. Arch Sex Behav. 1996;25(1):1-16. [pmid: 8714425].
Mann RD. Introduction - Tadalafil. Journal of Drug Evaluation. 2004;2(8):223.
Mann RD. Executive summary sildenafil citrate (Viagra). Journal of Drug Evaluation. 2003;1(7):221-223.
Manning M, Junemann KP, Scheepe JR, et al. Long-term followup and selection criteria for penile revascularization in erectile failure.[see comment]. Br J Urol. 1998;160(5):1680-1684.
Marberger M, Roehrborn CG, Marks LS, et al. Relationship among serum testosterone, sexual function, and response to treatment in men receiving dutasteride for benign prostatic hyperplasia. Journal of Clinical Endocrinology & Metabolism. 2006;91(4):1323-1328. [pmid: 16434455].
Margel D, Tal R, Livne PM, et al. Predictors of erectile function improvement in obstructive sleep apnea patients with long-term CPAP treatment. Int J Impot Res. 2005;17(2):186-190. [pmid: 15510189].
Mark SD, Keane TE, Vandemark RM, et al. Impotence following pelvic fracture urethral injury: incidence, aetiology and management. Br J Urol. 1995;75(1):62-64. [pmid: 7850299].
Markou S, Perimenis P, Gyftopoulos K, et al. Vardenafil (Levitra) for erectile dysfunction: a systematic review and meta-analysis of clinical trial reports. Int J Impot Res. 2004;16(6):470-478. [pmid: 15229625].
Marquer C, Bressolle F. Moxisylyte: A review of its pharmacodynamic and pharmacokinetic properties, and its therapeutic use in impotence. Fundam Clin Pharmacol. 1998;12(4):377-387. [pmid: 9711459].
Martin DJ, Badwan K, Parker M, et al. Transdermal application of verapamil gel to the penile shaft fails to infiltrate the tunica albuginea. Br J Urol. 2002;168(6):2483-2485.
Martins FE, Reis JP. Visual erotic stimulation test for initial screening of psychogenic erectile dysfunction: a reliable noninvasive alternative?. Br J Urol. 1997;157(1):134-139.
Masand PS, Ashton AK, Gupta S, et al. Sustained-release bupropion for selective serotonin reuptake inhibitor-induced sexual dysfunction: a randomized, double-blind, placebo-controlled, parallel-group study.[see comment]. Am J Psychiatry. 2001;158(5):805-807. [pmid: 11329407].
Matthew AG, Goldman A, Trachtenberg J, et al. Sexual dysfunction after radical prostatectomy: Prevalence, treatments, restricted use of treatments and distress. Br J Urol. 2005;174(6):2105-2110.
Maytom MC, Derry FA, Dinsmore WW, et al. A two-part pilot study of sildenafil (VIAGRA) in men with erectile dysfunction caused by spinal cord injury. Spinal Cord. 1999;37(2):110-116. [pmid: 10065749].
McCarthy Barry W. Relapse prevention strategies and techniques with erectile dysfunction. J Sex Marital Ther. 2001;27(1):1-8. [pmid: 11224950].
McClellan KJ, Goa KL. Transdermal testosterone. [Review] [17 refs]. Drugs. 1998;55(2):253-258. [pmid: 9506244].
McClure RD. Endocrine evaluation and therapy of erectile dysfunction. [Review] [77 refs]. Urol Clin North Am. 1988;15(1):53-64. [pmid: 3278476].
McConnell JD, Roehrborn CG, Bautista OM, et al. The Long-Term Effect of Doxazosin, Finasteride, and Combination Therapy on the Clinical Progression of Benign Prostatic Hyperplasia. N Engl J Med. 2003;349(25):2387-2398. [pmid: 14681504].
McCullough AR, Barada JH, Fawzy A, et al. Achieving treatment optimization with sildenafil citrate (Viagra) in patients with erectile dysfunction. Urology. 2002;60(2 Suppl 2):28-38. [pmid: 12414331].
McKinlay J B. The worldwide prevalence and epidemiology of erectile dysfunction. [Review][17 refs]. Int J Impot Res 2000;12Suppl-S11.
McMahon C. Comparison of erectile responses to differing doses of prostaglandin PGE1 in an attempt to standardise pharmacological diagnosis of impotence. Journal of Assisted Reproduction & Genetics 1992;9265A
McMahon CG. Nonsurgical treatment of cavernosal venous leakage. Urology. 1997;49(1):97-100. [pmid: 9000193].
McMahon CG. Treatment of Erectile Dysfunction with Chronic Dosing of Tadalafil. Eur Urol. 2006;50(2):215-217. [pmid: 16844542].
McMahon CG. Priapism associated with concurrent use of phosphodiesterase inhibitor drugs and intracavernous injection therapy. Int J Impot Res. 2003;15(5):383-384. [pmid: 14562142].
McMahon CG, Stuckey BGA, Andersen M, et al. Efficacy of sildenafil citrate (viagra) in men with premature ejaculation. Br J Sex Med. 2005;2(3):368-375.
Mealy NE. NBI-69733. Drugs of the Future. 2004;29(6):642.
Mealy NE. GPI-1485. Drugs of the Future. 2004;29(6):640.
Mealy NE. EMR-62203. Drugs of the Future. 2004;29(6):639.
Mealy NE. Dasantafil. Drugs of the Future. 2004;29(6):633.
Mealy NE. DA-8159. Drugs of the Future. 2004;29(6):631.
Mealy NE. Avanafil. Drugs of the Future. 2004;29(6):628-629.
Mealy NE. Alprostadil cream. Drugs of the Future. 2004;29(6):626-627.
Mealy NE, Bayes M. PT-141. Drugs of the Future. 2004;29(11):1177.
Mealy NE, Bayes M. ABT-724. Drugs of the Future. 2005;30(9):935.
Mehdiyev T V. Intracavernous injection probe of vasoactive preparations in the diagnosis of erectile dysfunctions in patients with diabetes mellitus. Azerbaidzhanskii Meditsinskii Zhurnal 2002;(pp 17–19):-19.
Meinhardt W, Kropman RF, Vermeij P, et al. The influence of medication on erectile function. Int J Impot Res. 1997;9(1):17-26. [pmid: 9138055].
Melman A, Bar-Chama N, McCullough A, et al. The first human trial for gene transfer therapy for the treatment of erectile dysfunction: preliminary results. Eur Urol. 2005;48(2):314-318. [pmid: 15964135].
Mendelson WB, Gujavarty K, Slintak C, et al. Reported sexual dysfunction in obstructive sleep apnea patients. Ann Clin Psychiatry. 1990;2(2):93-101.
Merrick GS, Wallner KE, Butler WM. Minimizing prostate brachytherapy-related morbidity. Urology. 2003;62(5):786-792. [pmid: 14624895].
Metawea B, El-Nashar AR, Gad-Allah A, et al. Intracavernous papaverine/phentolamine-induced priapism can be accurately predicted with color Doppler ultrasonography. Urology. 2005;66(4):858-860. [pmid: 16230153].
Meyhoff HH, Rosenkilde P, Bodker A. Non-invasive management of impotence with transcutaneous nitroglycerin. Br J Urol. 1992;69(1):88-90. [pmid: 1737261].
Migliari R, Muscas G, Usai E. Effect of Casodex on sleep-related erections in patients with advanced prostate cancer. Br J Urol. 1992;148(2 I):338-341.
Mikhail N. Efficacy and safety of sildenafil in patients with congestive heart failure [7]. Arch Intern Med. 2004;164(18):2067-2068. [pmid: 15477449].
Millard RJ, Stricker PD, Lynch WJ, et al. Risks of self-injection therapy for impotence. Med J Aust. 1996;165(2):117-118. [pmid: 8692055].
Miller DC, Wei JT, Dunn RL, et al. Use of medications or devices for erectile dysfunction among long-term prostate cancer treatment survivors: potential influence of sexual motivation and/or indifference. Urology. 2006;68(1):166-171. [pmid: 16844457].
Miller N, Smolkin ME, Bissonette E, et al. Undetectable prostate specific antigen at 6–12 months: a new marker for early success in hormonally treated patients after prostate brachytherapy. Cancer. 2005;103(12):2499-2506. [pmid: 15852361].
Mills RD, Sethia KK. Maximisation of the erectile response in the investigation of impotence. Int J Impot Res. 1999;11(1):29-32. [pmid: 10098951].
Mills TM, Lewis RW. The role of androgens in the erectile response: A 1999 perspective. Mol Urol. 1999;3(2):75-80. [pmid: 10851308].
Milman HA, Arnold SB, Rivera-Miranda G, et al. Neurologic, psychological, and aggressive disturbances with sildenafil. Ann Pharmacother. 2002;36(78):1129-1134. [pmid: 12086542].
Mirone VG, Stief CG. Efficacy of apomorphine SL in erectile dysfunction.[erratum appears in BJU Int 2002 Jan;89(1):140]. [Review] [11 refs]. BJU Int. 2001;88(Suppl 3):25-29. [pmid: 11578276].
Mittleman MA, Glasser DB, Orazem J. Clinical trials of sildenafil citrate (Viagra) demonstrate no increase in risk of myocardial infarction and cardiovascular death compared with placebo. Int J Clin Pract. 2003;57(7):597-600. [pmid: 14529061].
Mittleman MM, Rosen RC. Evaluating clinical trial design results and analysis of drug treatments for erectile dysfunction. Int J Impot Res. 2003;15(4):x-xiii.
Miwa Y, Kaneda T, Yokoyama O. Correlation between the Aging Males' Symptoms Scale and sex steroids, gonadotropins, dehydroepiandrosterone sulfate, and growth hormone levels in ambulatory men. Br J Sex Med. 2006;3(4):723-726.
Mohr BA, Bhasin S, Link CL, et al. The effect of changes in adiposity on testosterone levels in older men: longitudinal results from the Massachusetts Male Aging Study. Eur J Endocrinol. 2006;155(3):443-452. [pmid: 16914599].
Montejo A L, Llorca G, Izquierdo J A et al. Incidence of sexual dysfunction associated with antidepressant agents: a prospective multicenter study of 1022 outpatients. Spanish Working Group for the Study of Psychotropic-Related Sexual Dysfunction.[see comment]. Hillside J Clin Psychiatry 2001;62Suppl-21.
Montejo-Gonzalez AL, Llorca G, Izquierdo JA, et al. SSRI-induced sexual dysfunction: fluoxetine, paroxetine, sertraline, and fluvoxamine in a prospective, multicenter, and descriptive clinical study of 344 patients. Journal of Sex and Marital Therapy. 1997;23(3):176-194. [pmid: 9292833].
Montorsi F. A multicenter, randomized, double-blind, crossover study to evaluate patient preference between tadalafil and sildenafil: Editorial comment. Eur Urol. 2004;45(4):508-509.
Montorsi F, Althof SE. Partner responses to sildenafil citrate (Viagra) treatment of erectile dysfunction. Urology. 2004;63(4):762-767. [pmid: 15072897].
Montorsi F, Burnett AL. Erectile dysfunction after radical prostatectomy. BJU Int. 2004;93(1):1-2. [pmid: 14678354].
Montorsi F, Briganti A, Salonia A, et al. Current and Future Strategies for Preventing and Managing Erectile Dysfunction Following Radical Prostatectomy. Eur Urol. 2004;45(2):123-133. [pmid: 14733995].
Montorsi F, Briganti A, Salonia A, et al. Can Phosphodiesterase Type 5 Inhibitors Cure Erectile Dysfunction?. Eur Urol. 2006;49(6):979-986. [pmid: 16431013].
Montorsi F, Guazzoni G, Bocciardi A, et al. Improved minimally-invasive assessment of penile haemodynamics: the combination of colour Doppler sonography and injection-stimulation test. Int J Impot Res. 1995;7(1):33-40. [pmid: 7670591].
Montorsi F, Perani D, Anchisi D, et al. Brain activation patterns during video sexual stimulation following the administration of apomorphine: results of a placebo-controlled study. Eur Urol. 2003;43(4):405-411. [pmid: 12667722].
Montorsi F, Salonia A, Briganti A, et al. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol. 2005;47(5):612-621. [pmid: 15826752].
Montorsi F, Strambi LF, Guazzoni G, et al. Effect of yohimbine-trazodone on psychogenic impotence: a randomized, double-blind, placebo-controlled study. Urology. 1994;44(5):732-736. [pmid: 7974947].
Moore R A, Edwards J E, McQuay H J. Sildenafil (Viagra) for male erectile dysfunction: a meta-analysis of clinical trial reports. BMC Urol. 2002;26
Morales A. Men's aging and sexual disorders: An update on diagnosis and treatment. Rev Endocr Metab Disord. 2005;6(2):85-92. [pmid: 15843879].
Morales A, Gingell C, Collins M, et al. Clinical safety of oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):69-73. [pmid: 9647940].
Morales Alvaro, Condra Michael, Heaton Jeremy P, et al. Impotence: Organic factors and management approach. Sexual & Marital Therapy. 1991;6(2):97-106.
Moreira ED, Lbo CF, Diament A, et al. Incidence of erectile dysfunction in men 40 to 69 years old: results from a population-based cohort study in Brazil. Urology. 2003;61(2):431-436. [pmid: 12597962].
Moreira E D, Lisboa Lobo C F, Villa M et al. Prevalence and correlates of erectile dysfunction in Salvador, northeastern Brazil: a population-based study. Int J Impot Res 2002;14Suppl-9.
Morley John E, Kaiser Fran E. Aging and sexuality. Vellas, Bruno (Ed); Albarede, J 1992;-L(Ed):1992–165.
Mulhall JP. Deciphering erectile dysfunction drug trials. [Review] [35 refs]. Br J Urol. 2003;170(2 Pt 1):353-358.
Mulhall JP. Sublingual apomorphine for the treatment of erectile dysfunction. [Review] [22 refs]. Expert Opin Investig Drugs. 2002;11(2):295-302.
Mulhall JP, bdel-Moneim A, Abobakr R, et al. Improving the accuracy of vascular testing in impotent men: correcting hemodynamic alterations using a vasoactive medication re-dosing schedule. Br J Urol. 2001;166(3):923-926.
Mulhall JP, Daller M, Traish AM, et al. Intracavernosal forskolin: Role in management of vasculogenic impotence resistant to standard 3-agent pharmacotherapy. Br J Urol. 1997;158(5):1752-1759.
Mulhall JP, Levine LA, Junemann KP. Erection hardness: a unifying factor for defining response in the treatment of erectile dysfunction. [Review] [37 refs]. Urology. 2006;68(3 Suppl):17-25. [pmid: 17011372].
Mulligan T, Schmitt B. Testosterone for erectile failure. J Gen Intern Med. 1993;8(9):517-521. [pmid: 8410427].
Mulligan T, Frick MF, Zuraw QC, et al. Prevalence of hypogonadism in males aged at least 45 years: the HIM study. Int J Clin Pract. 2006;60(7):762-769. [pmid: 16846397].
Muneer A, Ralph DJ, Minhas S. Sildenafil citrate (Viagra). Journal of Drug Evaluation. 2003;1(7):225-246.
Munoz M, Bancroft J, Beard M. Evaluating the effects of an alpha-2 adrenoceptor antagonist on erectile function in the human male. 2. The erectile response to erotic stimuli in men with erectile dysfunction, in relation to age and in comparison with normal volunteers. Psychopharmacology (Berl). 1994;115(4):471-477. [pmid: 7871091].
Munoz M, Bancroft J, Turner M. Evaluating the effects of an alpha-2 adrenoceptor antagonist on erectile function in the human male. 1. The erectile response to erotic stimuli in volunteers. Psychopharmacology (Berl). 1994;115(4):463-470. [pmid: 7871090].
Murphy AM, O'Leary M. Failure of the Ambicor inflatable penile prosthesis to deflate. Int J Impot Res. 2005;17(3):291-292. [pmid: 15605073].
Murphy JC, Srinivas S, Terris MK. Flutamide administration at 500 mg daily has similar effects on serum testosterone to 750 mg daily. J Androl. 2004;25(4):630-634. [pmid: 15223852].
Nagai A, Kusumi N, Tsuboi H, et al. Intracavernous injection of prostaglandin E1 is effective in patients with erectile dysfunction not responding to phosphodiseterase 5 inhibitors. Acta Med Okayama. 2005;59(6):279-280. [pmid: 16418771].
Nakata M, Takashima S, Kaminou T, et al. Embolotherapy for venous impotence: use of ethanol. Journal of Vascular & Interventional Radiology. 2000;11(8):1053-1057. [pmid: 10997470].
Nakonezny PA, Byerly MJ, Rush AJ. The relationship between serum prolactin level and sexual functioning among male outpatients with schizophrenia or schizoaffective disorder: A randomized double-blind trial of risperidone vs. quetiapine. J Sex Marital Ther. 2007;33(3):203-216. [pmid: 17454518].
Nalesnik JG, Jones L, Kraus SR. Group B streptococcal septicemia following intracavernous injection therapy for erectile dysfunction in diabetes. Br J Urol. 2004;172(1):151-152.
Nandwani R, Gourlay Y. Possible interaction between sildenafil and HIV combination therapy [1]. Lancet. 1999;353(9155):840. [pmid: 10459981].
Narayan P, Trachtenberg J, Lepor H, et al. A dose-response study of the effect of flutamide on benign prostatic hyperplasia: results of a multicenter study. Urology. 1996;47(4):497-504. [pmid: 8638357].
Neese Leah E, Schover Leslie R, Klein Eric A, et al. Finding help for sexual problems after prostate cancer treatment: A phone survey of men's and women's perspectives. [References]. Psychooncology. 2003;12(5):463-473. [pmid: 12833559].
Nehra A, Blute ML, Barrett DM, et al. Rationale for combination therapy of intraurethral prostaglandin E(1) and sildenafil in the salvage of erectile dysfunction patients desiring noninvasive therapy. Int J Impot Res. 2002;14(Suppl 1):38-42. [pmid: 11896476].
Neumeyer K, Kirkpatrick P. Tadalafil and vardenafil. Nat Rev Genet. 2004;3(4):295-296.
Nicolosi A, Moreira ED, Shirai M, et al. Epidemiology of erectile dysfunction in four countries: cross-national study of the prevalence and correlates of erectile dysfunction. Urology. 2003;61(1):201-206. [pmid: 12559296].
Nieschlag E, Swerdloff R, Behre HM, et al. Investigation, treatment and monitoring of late-onset hypogonadism in males: ISA, ISSAM, and EAU recommendations. Int J Androl. 2005;28(3):125-127. [pmid: 15910536].
Nurnberg H G, Hensley P L. Sildenafil citrate for the management of antidepressant-associated erectile dysfunction. Hillside J Clin Psychiatry 2003;64Suppl-5.
Nurnberg HG, Gelenberg A, Hargreave TB, et al. Efficacy of sildenafil citrate for the treatment of erectile dysfunction in men taking serotonin reuptake inhibitors. Am J Psychiatry. 2001;158(11):1926-1928. [pmid: 11691705].
Nurnberg HG, Seidman SN, Gelenberg AJ, et al. Depression, antidepressant therapies, and erectile dysfunction: clinical trials of sildenafil citrate (Viagra) in treated and untreated patients with depression. Urology. 2002;60(2 Suppl 2):58-66. [pmid: 12414334].
Nurnberg H, George. Erectile Dysfunction and Comorbid Depression: Prevalence, Treatment Strategies, and Associated Medical Conditions. [References]. Hillside J Clin Psychiatry. 2003;64(Suppl10):3-4.
Nurnberg H, George Hensley, Paula L, et al. Sildenafil in the treatment of sexual dysfunction induced by selective serotonin reuptake inhibitors: An overview. [References]. CNS Drugs. 2000;13(5):321-335.
O'Sullivan JD. Apomorphine as an alternative to sildenafil in Parkinson's disease. [References]. Journal of Neurology, Neurosurgery & Psychiatry. 2002;72(5):681.
O'Sullivan JD, Hughes AJ. Apomorphine-induced penile erections in Parkinson's disease. Mov Disord. 1998;13(3):536-539. [pmid: 9613749].
Oefelein MG. Time to normalization of serum testosterone after 3-month luteinizing hormone-releasing hormone agonist administered in the neoadjuvant setting: implications for dosing schedule and neoadjuvant study consideration.[see comment]. Br J Urol. 1998;160(5):1685-1688.
Ohebshalom M, Mulhall JP. Transdermal and topical pharmacotherapy for male sexual dysfunction. Expert Opinion on Drug Delivery. 2005;2(1):115-120. [pmid: 16296739].
Ojumu A, Dobs AS. Is Hypogonadism a Risk Factor for Sexual Dysfunction?. J Androl. 2003;24(6 SUPPL.):S46-S51. [pmid: 14581495].
Onu PE. Depot medroxyprogesterone in the management of benign prostatic hyperplasia. Eur Urol. 1995;28(3):229-235. [pmid: 8536777].
Opsomer RJ, Wese FX, De Groote P, et al. The external vacuum device in the management of erectile dysfunction. Acta Urol Belg. 1997;65(4):13-16. [pmid: 9497591].
Ormrod D, Easthope SE, Figgitt DP. Vardenafil.[erratum appears in Drugs Aging 2002;19(11):886]. [Review] [30 refs]. Drugs Aging. 2002;19(3):217-227. [pmid: 12027779].
Osterloh IH, Riley A. Clinical update on sildenafil citrate. [Review] [58 refs]. Br J Clin Pharmacol. 2002;53(3):219-223. [pmid: 11874383].
Osterloh I H, Collins M, Wicker P et al. Sildenafil citrate (VIAGRA): overall safety profile in 18 double-blind, placebo controlled, clinical trials. [Review][0 refs]. Int J Clin Pract 1999;Supplement.102–105.
Owens J. Seeking selectivity. Nat Rev Genet. 2005;4(2):106.
Ozbek E, Yurekli M, Soylu A, et al. The role of adrenomedullin in varicocele and impotence. BJU Int. 2000;86(6):694-698. [pmid: 11069379].
Ozdel O, Oguzhanoglu A, Oguzhanoglu NK, et al. A follow-up study of male sexual disorders: The neurophysiological assessments, anxiety-depression levels, and response to fluoxetine treatment [10]. J Clin Psychopharmacol. 2004;24(4):461-463. [pmid: 15232347].
Padma-Nathan H, Eardley I, Kloner RA, et al. A 4-year update on the safety of sildenafil citrate (Viagra). [Review] [88 refs]. Urology. 2002;60(2:Suppl 2):Suppl-90.
Pagani E, Glina S, Puech-Leao P, et al. Anxiety and high plasma catecholamines do not impair pharmaco-induced erection of psychogenic erectile dysfunctional patients. Int J Impot Res. 2003;15(4):282-286. [pmid: 12934057].
Paice Judith A, Penn Richard D, Ryan Will G. Altered sexual function and decreased testosterone in patients receiving intraspinal opioids. J Pain Symptom Manage. 1994;9(2):126-131. [pmid: 7517429].
Paick JS, Yang JH, Kim SW, et al. Severity of erectile dysfunction in married impotent patients: interrelationship with anthropometry, hormones, metabolic profiles and lifestyle. Int J Urol. 2007;14(1):48-53. [pmid: 17199860].
Paick JS, Yang JH, Kim SW, et al. The role of prolactin levels in the sexual activity of married men with erectile dysfunction. BJU Int. 2006;98(6):1269-1273. [pmid: 17125484].
Paick SH, Meehan A, Lee M, et al. The relationship among lower urinary tract symptoms, prostate specific antigen and erectile dysfunction in men with benign prostatic hyperplasia: results from the proscar long-term efficacy and safety study. Br J Urol. 2005;173(3):903-907.
Palha AP, Gomes FA, Martins AS, et al. [Clinical, multicentric, and open study to evaluate the efficacy of and tolerance to sildenafil in patients with erectile dysfunction]. Acta Med Port. 2002;15(4):249-256. [pmid: 12525018].
Pan CC, Lin JSN, Wong WS. Comparison of effect on erection between vacuum constriction devices and intra-cavernous injection of prostaglandin E1. Asian J Surg. 1997;20(2):162-166.
Papatsoris AG, Deliveliotis C, Singer C, et al. Erectile dysfunction in Parkinson's disease. Urology. 2006;67(3):447-451. [pmid: 16504269].
Parazzini F, Menchini Fabris F, Bortolotti A, et al. Frequency and determinants of erectile dysfunction in Italy. Eur Urol. 2000;37(1):43-49. [pmid: 10671784].
Paris G, Sponsel WE, Sandoval SS, et al. Sildenafil increases ocular perfusion. Int Ophthalmol. 2001;23(46):355-358. [pmid: 11944862].
Parker C. The Scandinavian Prostate Cancer Group Study: The case for conservative management. BJU Int. 2005;96(7):952-953. [pmid: 16225505].
Parsons JK, Marschke P, Maples P, et al. Effect of methylprednisolone on return of sexual function after nerve-sparing radical retropubic prostatectomy. Urology. 2004;64(5):987-990. [pmid: 15533491].
Patankar M. Sildenafil citrate. J Indian Med Assoc 2000;98(12):
Patterson D, Kloner R, Effron M, et al. The effect of tadalafil on the time to exercise-induced myocardial ischaemia in subjects with coronary artery disease. Br J Clin Pharmacol. 2005;60(5):459-468. [pmid: 16236035].
Pegge NC, Twomey AM, Vaughton K, et al. The role of endothelial dysfunction in the pathophysiology of erectile dysfunction in diabetes and in determining response to treatment. Diabet Med. 2006;23(8):873-878. [pmid: 16911625].
Penninga E, Jensen BA, Hansen PB, et al. Anagrelide treatment in 52 patients with chronic myeloproliferative diseases. Clinical & Laboratory Haematology. 2004;26(5):335-340. [pmid: 15485463].
Penson DF, Feng Z, Kuniyuki A, et al. General quality of life 2 years following treatment for prostate cancer: what influences outcomes? Results from the prostate cancer outcomes study.[see comment]. Am J Clin Oncol. 2003;21(6):1147-1154.
Perez Martin A, Skinner Eila C, Meyerowitz Beth EE. Sexuality and intimacy following radical prostatectomy: Patient and partner perspectives. [References]. Health Psychol. 2002;21(3):288-293. [pmid: 12027035].
Perimenis P, Athanasopoulos A, Papathanasopoulos P, et al. Gabapentin in the management of the recurrent, refractory, idiopathic priapism. Int J Impot Res. 2004;16(1):84-85. [pmid: 14963477].
Pescatori ES, Calpista A, Artibani W, et al. Self-injection devices for intracavernosal pharmacotherapy: operational classification and safety considerations. Int J Impot Res. 1996;8(2):53-57. [pmid: 8858390].
Pescatori ES, Silingardi V, Galeazzi GM, et al. Audiovisual sexual stimulation by virtual glasses is effective in inducing complete cavernosal smooth muscle relaxation: a pharmacocavernosometric study. Int J Impot Res. 2000;12(2):83-88. [pmid: 11052633].
Phelps JS, Jain A, Monga M. The PsychoedPlusMed approach to erectile dysfunction treatment: the impact of combining a psychoeducational intervention with sildenafil. J Sex Marital Ther. 2004;30(5):305-314. [pmid: 15672598].
Philipp M, Kohnen R, Benkert O. A comparison study of moclobemide and doxepin in major depression with special reference to effects on sexual dysfunction. Int Clin Psychopharmacol. 1993;7(34):149-153. [pmid: 8468436].
Philipp M, Tiller JWG, Baier D, et al. Comparison of moclobemide with selective serotonin reuptake inhibitors (SSRIs) on sexual function in depressed adults. Eur Neuropsychopharmacol. 2000;10(5):305-314. [pmid: 10974600].
Phillips BG, Kato M, Pesek CA, et al. Sympathetic activation by sildenafil.[see comment]. Circulation. 2000;102(25):3068-3073. [pmid: 11120696].
Pirotte B, de Tullio P, Antoine MH, et al. New insights into the development of ATP-sensitive potassium channel openers. Expert Opinion on Therapeutic Patents. 2005;15(5):497-504.
Pisters LL, von Eschenbach AC, Scott SM, et al. The efficacy and complications of salvage cryotherapy of the prostate. J Urol. 1997;157(3):921-925. [pmid: 9072600].
Pittler M, Ernst E. Trials have shown yohimbine is effective for erectile dysfunction [14]. Br Med J. 1998;317(7156):478. [pmid: 9703549].
Polak K, Wimpissinger B, Berisha F, et al. Effects of sildenafil on retinal blood flow and flicker-induced retinal vasodilatation in healthy subjects. Invest Ophthalmol Vis Sci. 2003;44(11):4872-4876. [pmid: 14578411].
Pollack Mark H, Reiter Stewart, Hammerness Paul. Genitourinary and sexual adverse effects of psychotropic medication. Int J Psychiatry Med. 1992;22(4):305-327. [pmid: 1363418].
Pomara G, Morelli G, Montorsi F et al. Re: Montorsi F, Salonia A, Briganti A, Barbieri L, Zanni G, Surdi N, Cestari A, Montorsi P, Rigatti P. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol 2005;47:61–1 (multiple letters). Eur Urol 2005;48(2):345–346.
Pomerantz JM. Viagra and medical necessity. Drug Benefit Trends. 2002;14(10):33-40.
Pommerville P. Drug treatments for erectile dysfunction: An update. Geriatrics and Aging. 2004;7(6):10-16.
Pommerville P J. From bedside to bed. Recovery of sexual function after prostate cancer. Can Fam Physician 2005;51(JULY):941–943+948.
Porst H. IC351 (tadalafil, Cialis): update on clinical experience. [Review][12 refs]. Int J Impot Res 2002;14Suppl-64.
Porst H. Phosphodiesterase type-5 inhibitors: A critical comparative analysis. Eau Update Series. 2004;2(2):56-63.
Porst HC. Re-dosing of prostaglandin-E1 versus prostaglandin-E1 plus phentolamine in male erectile dysfunction: a dynamic color power Doppler study. Int J Impot Res. 2000;12(2):134-135. [pmid: 11052645].
Porst H, Giuliano F, Glina S, et al. Evaluation of the Efficacy and Safety of Once-a-Day Dosing of Tadalafil 5 mg and 10 mg in the Treatment of Erectile Dysfunction: Results of a Multicenter, Randomized, Double-Blind, Placebo-Controlled Trial. Eur Urol. 2006;50(2):351-359. [pmid: 16766116].
Pouaha J, Martin S, Reichert-Penetrat S, et al. Thalidomide and sexual dysfunction in men.[comment]. Br J Dermatol. 2002;146(6):1112-1113. [pmid: 12072099].
Power-Smith Parsley. Beneficial sexual side-effects from fluoxetine. Br J Psychiatry Suppl 1994;164 Feb 1994, 249–250. http249–250.
Pradeep C, Car N, Metelko Z. Impotence in diabetic men. Diabetol Croat. 1996;25(2):61-68.
Pratt-Ubunama MN, Nishizaka MK, Calhoun DA. Aldosterone antagonism: An emerging strategy for effective blood pressure lowering. Curr Hypertens Rep. 2005;7(3):186-192. [pmid: 15913492].
Preskorn SH. Duloxetine. Journal of Psychiatric Practice. 2004;10(6):375-385. [pmid: 15583519].
Price DE, Cooksey G, Jehu D, et al. The management of impotence in diabetic men by vacuum tumescence therapy. Diabet Med. 1991;8(10):964-967. [pmid: 1838050].
Prins J, Blanker MH, Bohnen AM, et al. Prevalence of erectile dysfunction: A systematic review of population-based studies. Int J Impot Res. 2002;14(6):422-432. [pmid: 12494273].
Priyadarshi S. Oral terbutaline in the management of pharmacologically induced prolonged erection. Int J Impot Res. 2004;16(5):424-426. [pmid: 14999218].
Pryor J. Vardenafil: update on clinical experience. [Review][10 refs]. Int J Impot Res 2002;14Suppl-9.
Pryor JP. Orgasmic and ejaculatory dysfunction. Sexual & Relationship Therapy. 2002;17(1):87-95.
Qian LX, Wu HF, Xu H, et al. Multi-center Evaluation of Efficacy and Safety of Oral Mesylate Phentolamine for the Treatment of Erectile Dysfunction. Int J Androl. 2001;7(5):302-305.
Quinn MJ, Jefferson K, Persad R. Benign prostatic hyperplasia and sexual dysfunction [3] (multiple letters). Lancet. 2003;361(9368):1562. [pmid: 12737897].
Quirk J, Thornton M, Neumeyer K, et al. Cardiology and vascular disorders. Nat Rev Genet. 2004;3(7 SUPPL.):S12-S17.
Radomski SB, Herschorn S, Rangaswamy S. Topical minoxidil in the treatment of male erectile dysfunction. Br J Urol. 1994;151(5):1225-1226.
Ramasubbu R. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Ramasubbu Rajamannar. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Ramasubbu Rajamannar. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Rashid A. The efficacy and safety of PDE5 inhibitors. [Review] [30 refs]. Clin Cornerstone. 2005;7(1):47-56. [pmid: 16156423].
Reffelmann T, Kloner RA. Effects of sildenafil on myocardial infarct size, microvascular function, and acute ischemic left ventricular dilation. Cardiovasc Res. 2003;59(2):441-449. [pmid: 12909327].
Reyes JA, Tan DA, Quimpo JA, et al. The Philippine Male Aging Survey. Aging Male. 2004;7(3):227-235. [pmid: 15669542].
Rhoden EL, Estrada C, Levine L, et al. The value of pituitary magnetic resonance imaging in men with hypogonadism.[see comment]. Br J Urol. 2003;170(3):795-798.
Richardson JD. Intracorporeal injections for the treatment of impotence. Med J Aust. 1991;155(10):688. [pmid: 1943899].
Richter S, Vardi Y, Ringel A, et al. Intracavernous injections: still the gold standard for treatment of erectile dysfunction in elderly men. Int J Impot Res. 2001;13(3):172-175. [pmid: 11525316].
Riley Alan. Oral treatments for erectile dysfunction. Int J STD AIDS. 1996;7(Suppl 3):16-18. [pmid: 8876375].
Rizvi K, Hampson JP, Harvey JN. Do lipid-lowering drugs cause erectile dysfunction? A systematic review.[see comment]. [Review] [35 refs]. Fam Pract. 2002;19(1):95-98. [pmid: 11818357].
Roach M, Winter K, Michalski JM, et al. Penile bulb dose and impotence after three-dimensional conformal radiotherapy for prostate cancer on RTOG 9406: findings from a prospective, multi-institutional, phase I/II dose-escalation study. Int J Radiat Oncol Biol Phys. 2004;60(5):1351-1356. [pmid: 15590164].
Rodrigues M, Granegger S, O'Grady J, et al. Accumulation of platelets as a key mechanism of human erection. A scintigraphic study in patients with erectile dysfunction receiving intracavernous injection of PGE1, papaverine/phentolamine. Advances in Experimental Medicine & Biology. 1997;43:379-82.
Roizenblatt S, Guilleminault C, Poyares D, et al. A double-blind, placebo-controlled, crossover study of sildenafil in obstructive sleep apnea. Arch Intern Med. 2006;166(16):1763-1767. [pmid: 16983056].
Rojewski MT, Korper S, Schrezenmeier H. Arsenic trioxide therapy in acute promyelocytic leukemia and beyond: From bench to bedside. Leuk Lymphoma. 2004;45(12):2387-2401. [pmid: 15621751].
Rosano GM, Marazzi G, Patrizi R, et al. Comparison of trimetazidine plus sildenafil to chronic nitrates in the control of myocardial ischemia during sexual activity in patients with coronary artery disease. Am J Cardiol. 2005;95(3):327-331. [pmid: 15670539].
Rosas-Vargas H, Coral-Vazquez RM, Tapia R, et al. Glu298Asp endothelial nitric oxide synthase polymorphism is a risk factor for erectile dysfunction in the Mexican Mestizo population. J Androl. 2004;25(5):728-732. [pmid: 15292102].
Rose VL. Sildenafil in the treatment of erectile dysfunction. Am Fam Physician. 1998;58(1):268.
Rosen RC, Kostis JB. Overview of phosphodiesterase 5 inhibition in erectile dysfunction. Am J Cardiol. 2003;92(9 SUPPL. 1):9M-18M.
Rosen RC, Lane RM, Menza M. Effects of SSRIs on sexual function: a critical review.[see comment]. [Review] [255 refs]. J Clin Psychopharmacol. 1999;19(1):67-85. [pmid: 9934946].
Rosen RC, Shabsigh R, Kuritzky L, et al. The efficacy of tadalafil in improving sexual satisfaction and overall satisfaction in men with mild, moderate, and severe erectile dysfunction: A retrospective pooled analysis of data from randomized, placebo-controlled clinical trials. Current Medical Research & Opinion. 2005;21(11):1701-1709. [pmid: 16307689].
Rosen Raymond C. Erectile dysfunction: The medicalization of male sexuality. Clin Psychol Rev. 1996;16(6):497-519.
Rosen Raymond C, Leiblum Sandra R. Treatment of male erectile disorder: Current options and dilemmas. Sexual & Marital Therapy. 1993;8(1):5-8.
Rosen Raymond C, Leiblum Sandra, Risa. Erectile disorders: An overview of historical trends and clinical perspectives. Rosen, Raymond C (Ed); Leiblum, Sandra Risa (Ed) 1992;(1992):378
Rosenthal BD, May NR, Metro MJ, et al. Adjunctive use of AndroGel (testosterone gel) with sildenafil to treat erectile dysfunction in men with acquired androgen deficiency syndrome after failure using sildenafil alone. Urology. 2006;67(3):571-574. [pmid: 16527581].
Rowland DL, Greenleaf WJ, Dorfman LJ, et al. Aging and sexual function in men. Arch Sex Behav. 1993;22(6):545-557. [pmid: 8285844].
Rowland DL, Kallan K, Slob AK. Yohimbine, erectile capacity, and sexual response in men. Arch Sex Behav. 1997;26(1):49-62. [pmid: 9015579].
Rudkin L, Taylor M J, Hawton K. Strategies for managing sexual dysfunction induced by antidepressant medication. [Review][61 refs]. Cochrane Database Syst Rev 2004;(4):CD003382
Ruof J, Graf-Morgenstern M, Mnller MJ. Quality of life in patients with erection difficulties: Evaluation of a German version of the “Quality of life measure for men with erection difficulties” (QoL-Med). Aktuel Urol. 2001;32(1):21-26.
Ryder RE, Close CF, Moriarty KT, et al. Impotence in diabetes: aetiology, implications for treatment and preferred vacuum device. Diabet Med. 1992;9(10):893-898. [pmid: 1478032].
Saad F, Grahl AS, Aversa A, et al. Effects of testosterone on erectile function: implications for the therapy of erectile dysfunction. BJU Int. 2007;99(5):988-992. [pmid: 17309554].
Saad F, Hoesl CE, Oettel M, et al. Dehydroepiandrosterone treatment in the aging male - What should the urologist know?. Eur Urol. 2005;48(5):724-733. [pmid: 16137821].
Sadock Virginia A. A sexually compulsive male with erectile dysfunction treated with Viagra: Discussion. Journal of Sex Education & Therapy. 1998;23(4):275-277.
Safarinejad MR. Prevalence and risk factors for erectile dysfunction in a population-based study in Iran. Int J Impot Res. 2003;15(4):246-252. [pmid: 12934051].
Sairam K, Kulinskaya E, Boustead GB, et al. Prevalence of undiagnosed prostate cancer in men with erectile dysfunction. BJU Int. 2002;89(3):261-263. [pmid: 11856107].
Sak SC, Eardley I. What is the relationship between benign prostatic hyperplasia and sexual function?. Sexual & Relationship Therapy. 2004;19(4):431-443.
Sakamoto H, Shimada M, Yoshida H. Hemodynamic evaluation of the penile arterial system in patients with erectile dysfunction using power doppler imaging. Urology. 2002;60(3):480-484. [pmid: 12350490].
Saks Bonnie R. A sexually compulsive male with erectile dysfunction treated with Viagra: Case report. Journal of Sex Education & Therapy. 1998;23(4):271-274.
Salonia A, Barbieri L, Chen J, et al. Comparison of the effect of sildenafil and apomorphine SL on nocturnal erections in healthy volunteers: a placebo-controlled study. Eur Urol. 2005;47(4):524-529. [pmid: 15774253].
Salonia A, Maga T, Colombo R, et al. A prospective study comparing paroxetine alone versus paroxetine plus sildenafil in patients with premature ejaculation. Br J Urol. 2002;168(6):2486-2489.
Salonia A, Rigatti P, Montorsi F. Sildenafil in erectile dysfunction: a critical review. Curr.Med Res Opin. 2003;19(4):241-262. [pmid: 12841917].
Salonia Andrea, Briganti Alberto, Montorsi Piero, et al. Safety and tolerability of oral erectile dysfunction treatments in the elderly. [References]. Drugs and Aging. 2005;22(4):323-338. [pmid: 15839721].
Samarasinghe Y, Rivas-Toro H. HEART UK 18th annual medical and scientific meeting: From diabetes to mixed hyperlipidaemias. British Journal of Cardiology. 2004;11(5):364-365.
Sathe RS, Komisaruk BR, Ladas AK, et al. Naltrexone-induced augmentation of sexual response in men. Arch Med Res. 2001;32(3):221-226. [pmid: 11395188].
Sato Y, Horita H, Adachi H, et al. Effect of oral administration of prostaglandin E1 on erectile dysfunction. Br J Urol. 1997;80(5):772-775. [pmid: 9393301].
Sato Y, Suzuki N, Adachi H, et al. Evaluation of the alleviative action of neurotropin for penile pain associated with intracavernous injection of prostaglandin E1 assessed using the visual analogue scale. Int J Impot Res. 1998;10(1):1-3. [pmid: 9542683].
Savoca G, Silvestre G, Belgrano E. Intracavernosal injection therapy and surgical therapy in diabetic patients with erectile dysfunction. [Review] [26 refs]. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):53-57.
Scalvini T, Martini P R, Obici L et al. Infertility and Hypergonadotropic Hypogonadism as First Evidence of Hereditary Apolipoprotein A-I Amyloidosis. Br J Urol 2007;
Schiavi Raul C, Schanzer Harry, Sozio Giampaolo, et al. Erectile function and penile blood pressure in diabetes mellitus. J Sex Marital Ther. 1994;20(2):119-124. [pmid: 8035468].
Schimmer AD, Ali V, Stewart AK, et al. Male sexual function after autologous blood or marrow transplantation. Biology of Blood & Marrow Transplantation. 2001;7(5):279-283. [pmid: 11400950].
Scholz M, Strum S. Re: Recovery of spontaneous erectile function after nerve-sparing radical retropubic prostatectomy with and without early intracavernous injections of alprostadil: results of a prospective, randomized trial.[comment]. Br J Urol. 1999;161(6):1914-1915.
Schouman M, Lacroix P, Amer M. Suppression of prostaglandin E1-induced pain by dilution of the drug with lidocaine before intracavernous injection. Br J Urol. 1992;148(4):1266.
Schrader S, Mills A, Scheperle M, et al. Improvement in sexual functioning and satisfaction in nonresponders to testosterone gel: clinical effectiveness in hypogonadal, HIV-positive males. Clin Cornerstone. 2005;7(Suppl 4):S26-S31. [pmid: 16651205].
Schroder FH, Whelan P, De Reijke TM, et al. Metastatic prostate cancer treated by flutamide versus cyproterone acetate. Final analysis of the “European Organization for Research and Treatment of Cancer” (EORTC) Protocol 30892. Eur Urol. 2004;45(4):457-464. [pmid: 15041109].
Schultheiss D, Stief CG. Physiology and pathophysiology of erection: Consequences for present medical therapy of erectile dysfunction. Andrologia. 1999;31(SUPPL. 1):59-64. [pmid: 10643521].
Schwartz EJ, Wong P, Graydon RJ. Sildenafil preserves intracorporeal smooth muscle after radical retropubic prostatectomy. Br J Urol. 2004;171(2 I):771-774.
Seftel A. Male and female sexual function and dysfunction; andrology. Br J Urol. 2005;174(6):2297-2300.
Seftel A. Effect of lifestyle changes on erectile dysfunction in obese men. A randomized controlled trial. Br J Urol. 2005;173(2):544-545.
Seftel AD. From aspiration to achievement: Assessment and noninvasive treatment of erectile dysfunction in aging men. J Am Geriatr Soc. 2005;53(1):119-130. [pmid: 15667388].
Seftel AD. Male and female sexual function and dysfunction; andrology. Br J Urol. 2005;174(4 I):1364-1366.
Segraves RT. Pharmacological enhancement of human sexual behavior. Journal of Sex Education & Therapy. 1991;17(4):283-289.
Segraves R, Taylor. Two additional uses for sildenafil in psychiatric patients. [References]. J Sex Marital Ther. 1999;25(4):265-266. [pmid: 10546163].
Segraves Robert, Taylor Segraves, Kathleen Blindt, et al. Sexual function in patients taking bupropion sustained release. Hillside J Clin Psychiatry. 1995;56(8):374.
Seidman Stuart N. Exploring the relationship between depression and erectile dysfunction in aging men. Hillside J Clin Psychiatry. 2002;63(Suppl5):5-12.
Setter SM, Iltz JL, Fincham JE, et al. Phosphodiesterase 5 inhibitors for erectile dysfunction. [Review] [75 refs]. Ann Pharmacother. 2005;39(78):1286-1295. [pmid: 15941818].
Seyam RM, Albakry A, Ghobish A, et al. Prevalence of erectile dysfunction and its correlates in Egypt: a community-based study. Int J Impot Res. 2003;15(4):237-245. [pmid: 12934050].
Shabbir M, Mikhailidis DM, Morgan RJ. Erectile dysfunction: an underdiagnosed condition associated with multiple risk factors.[comment]. Current Medical Research & Opinion. 2004;20(5):603-606. [pmid: 15140326].
Shabbir M, Shah JS, Kirby RS. Cardiac failure and benign prostatic hyperplasia: Management of common comorbidities. BJU Int. 2005;95(3):278-280. [pmid: 15679777].
Shabsigh R. Testosterone therapy in erectile dysfunction. [Review] [34 refs]. Aging Male. 2004;7(4):312-318. [pmid: 15799127].
Shabsigh R. Testosterone therapy in erectile dysfunction and hypogonadism. Br J Sex Med. 2005;2(6):785-792.
Shabsigh R. Hypogonadism and erectile dysfunction: The role for testosterone therapy. Int J Impot Res. 2003;15(SUPPL. 4):S9-S13. [pmid: 12934045].
Shabsigh R, Katz M, Yan G, et al. Cardiovascular issues in hypogonadism and testosterone therapy. [Review] [44 refs]. Am J Cardiol. 2005;96(12B):67M-72M. [pmid: 15979436].
Shakir SAW, Wilton LV, Boshier A, et al. Cardiovascular events in users of sildenafil: Results from first phase of prescription event monitoring in England. Br Med J. 2001;322(7287):651-652. [pmid: 11250850].
Shamloul R. Management of honeymoon impotence. Br J Sex Med. 2006;3(2):361-366.
Shamloul R, El-Dakhly M, Ghanem H, et al. Intracavernous chlorpromazine versus phentolamine: A double-blind clinical comparative study. Br J Sex Med. 2004;1(3):310-313.
Shamloul R, Ghanem HM, Salem A, et al. The value of penile duplex in the prediction of intracavernous drug-induced priapism. Int J Impot Res. 2004;16(1):78-79. [pmid: 14961063].
Shamsa A, Motavalli SM, Aghdam B. Erectile function in end-stage renal disease before and after renal transplantation. Transplant Proc. 2005;37(7):3087-3089. [pmid: 16213314].
Sharlip ID. Editorial comment. International Braz J Urol. 2005;31(4):354-355.
Sharlip ID. Can self-injection therapy cure impotence?. [Review] [7 refs]. Advances in Experimental Medicine & Biology. 1997;43:383-86.
Shimon I, Lubina A, Gorfine M, et al. Feedback inhibition of gonadotropins by testosterone in men with hypogonadotropic hypogonadism: comparison to the intact pituitary-testicular axis in primary hypogonadism. J Androl. 2006;27(3):358-364. [pmid: 16474013].
Siegel RL, Dubin NH, Andrade JR. Sildenafil citrate and sperm function [3] (multiple letters). American Journal of Obstetrics & Gynecology. 2001;184(4):777-778. [pmid: 11262489].
Sighinolfi MC, de Stefani S, Mofferdin A, et al. Intracavernous prostaglandin E1 infusion in diabetes with associated ischemic necrosis of the glans penis. Br J Urol. 2004;171(6 I):2380.
Silvestri A, Galetta P, Cerquetani E, et al. Report of erectile dysfunction after therapy with beta-blockers is related to patient knowledge of side effects and is reversed by placebo.[see comment]. Eur Heart J. 2003;24(21):1928-1932. [pmid: 14585251].
Singer Carlos, Weiner William J, Sanchez-Ramos J, et al. Sexual function in patients with Parkinson's disease. Journal of Neurology, Neurosurgery & Psychiatry. 1991;54(10):942.
Sipski M, Alexander C, Guo X, et al. Cardiovascular effects of sildenafil in men with SCIs at and above T6. Topics in Spinal Cord Injury Rehabilitation. 2003;8(3):26-34.
Siraj QH, Bomanji J, Akhtar MA, et al. Quantitation of pharmacologically-induced penile erections: The value of radionuclide phallography in the objective evaluation of erectile haemodynamics. Nucl Med Commun. 1990;11(6):445-458. [pmid: 2385430].
Slob AK, Dohle GR, Incrocci L. ‘Sildenafil and pharmaco-penile duplex ultrasonography’ by Speel et al: Inconclusive results. Int J Impot Res. 2002;14(2):136-137. [pmid: 11979331].
Slob A, Koos Steyvers, Christel L, et al. Routine psychophysiological screening of 384 men with erectile dysfunction. J Sex Marital Ther. 1998;24(4):273-279. [pmid: 9805287].
Smith KJ, Roberts MS. The cost-effectiveness of sildenafil. Ann Intern Med. 2000;132(12):933-937. [pmid: 10858175].
Smith KM, Romanelli F. Recreational use and misuse of phosphodiesterase 5 inhibitors. [Review] [56 refs]. Journal of the American Pharmacists Association: JAPhA. 2005;45(1):63-72. [pmid: 15730119].
Sobh MA, el Hamid I Abd, et al. Effect of erythropoietin on sexual potency in chronic haemodialysis patients. A preliminary study. Scand J Urol Nephrol. 1992;26(2):181-185. [pmid: 1626208].
Sogari PR, Teloken C, Souto CA. Atropine role in the pharmacological erection test: study of 228 patients. Br J Urol. 1997;158(5):1760-1763.
Sohle GR. Re: The age-related decrease in testosterone is significantly exacerbated in obese men with the metabolic syndrome. What are the implications for the relatively high incidence of erectile dysfunction observed in these men?. Eur Urol. 2007;51(5):1440. [pmid: 17494117].
Sohn Michael, Sikora Richard. Ginkgo biloba extract in the therapy of erectile dysfunction. Journal of Sex Education & Therapy. 1991;17(1):53-61.
Solursh L, Solursh DS. Male erectile disorders in Vietnam combat veterans with chronic post-traumatic stress disorder. International Journal of Adolescent Medicine & Health. 1994;7(2):119-124. [pmid: 22912152].
Solursh Lionel P, Solursh Diane S. Male erectile disorders in Vietnam combat veterans with chronic post-traumatic stress disorder. Int J Adolesc Med Health. 1994;7(2):119-124. [pmid: 22912152].
Sonda LP, Mazo R, Chancellor MB. The role of yohimbine for the treatment of erectile impotence. J Sex Marital Ther. 1990;16(1):15-21. [pmid: 2370671].
Sonksen J, Biering-Sorensen F. Transcutaneous nitroglycerin in the treatment of erectile dysfunction in spinal cord injured. Paraplegia. 1992;30(8):554-557. [pmid: 1522996].
Sorbera LA, Martin L, Rabasseda X, et al. Vardenafil. Treatment of erectile dysfunction. Phosphodiesterase 5 inhibitor. Drugs of the Future. 2001;26(2):141-144.
Sparwasser C, Drescher P, Pust RA, et al. Long-term results of therapy with intracavernousal injections and penile venous surgery in chronic erectile dysfunction. Scand J Urol Nephrol Suppl. 1994;157(Suppl):107-112. [pmid: 7939440].
Speakman MT, Kloner RA. Viagra and cardiovascular disease. Journal of Cardiovascular Pharmacology & Therapeutics. 1999;4(4):259-267. [pmid: 10684547].
Srilatha B, Adaikan PG, Chong YS. Relevance of oestradiol-testosterone balance in erectile dysfunction patients' prognosis. Singapore Med J. 2007;48(2):114-118. [pmid: 17304389].
Stas SN, Anastasiadis AG, Fisch H, et al. Urologic aspects of andropause. Urology. 2003;61(2):261-266. [pmid: 12597927].
Steers WD. Tachyphylaxis and phosphodiesterase type 5 inhibitors.[comment]. Br J Urol. 2002;168(1):207.
Steers WD. Viagra - After one year. Urology. 1999;54(1):12-17. [pmid: 10414719].
Steidle C, Witt MA, Matrisciano J, et al. Sexual functioning and satisfaction in nonresponders to testosterone gel: Potential effectiveness of retreatment in hypogonadal males. Clin Cornerstone. 2005;7(Suppl 4):S20-S25. [pmid: 16651204].
Steiger A, Holsboer F, Benkert O. Studies of nocturnal penile tumescence and sleep electroencephalogram in patients with major depression and in normal controls. Acta Psychiatr Scand. 1993;87(5):358-363. [pmid: 8517177].
Steiger Axel, Benkert O, Holsboer F. Effects of long-term treatment with the MAO-A inhibitor moclobemide on sleep EEG and nocturnal hormonal secretion in normal men. Neuropsychobiology. 1994;30(23):101-105. [pmid: 7800155].
Stief CG, Uckert S, Jonas U. Strategies in the oral pharmacotherapy of male erectile dysfunction viewed from bench and bedside (Part II). The Journal of Mens Health & Gender. 2005;2(3):325-332.
Stief CG, Uckert S, Becker AJ, et al. The effect of the specific phosphodiesterase (PDE) inhibitors on human and rabbit cavernous tissue in vitro and in vivo. Br J Urol. 1998;159(4):1390-1393.
Stief C, Padley RJ, Perdok RJ, et al. Cross-study review of the clinical efficacy of apomorphine SL 2 and 3 mg: Pooled data from three placebo-controlled, fixed-dose crossover studies. European Urology Supplements. 2002;1(3):12-20.
Stolk EA, Busschbach JJ, Caffa M, et al. Cost utility analysis of sildenafil compared with papaverine-phentolamine injections.[see comment]. BMJ. 2000;320(7243):1165-1168. [pmid: 10784537].
Strachan MW, Teoh WL, Don-Wauchope AC, et al. Clinical and radiological features of patients with macroprolactinaemia. Clin Endocrinol (Oxf). 2003;59(3):339-346. [pmid: 12919157].
Strahilevitz J, Rahav G, Schroers HJ, et al. An outbreak of Phialemonium infective endocarditis linked to intracavernous penile injections for the treatment of impotence. Clin Infect Dis. 2005;40(6):781-786. [pmid: 15736008].
Stroberg P, Murphy A, Costigan T. Switching patients with erectile dysfunction from sildenafil citrate to tadalafil: results of a European multicenter, open-label study of patient preference. Clin Ther. 2003;25(11):2724-2737. [pmid: 14693300].
Struthers AD. Aldosterone blockade in heart failure. J Renin Angiotensin Aldosterone Syst. 2004;5(SUPPL. 1):S23-S27. [pmid: 15526239].
Stuckey BGA. Tadalafil phase 3 experience. European Urology Supplements. 2002;1(8):25-30.
Suetomi T, Endo F, Takeshima H, et al. Evaluation of the effectiveness of sildenafil using questionnaire methods versus audio-visual sexual stimulation. Int J Urol. 2005;12(4):369-373. [pmid: 15948724].
Suzuki F, Shimizu C, Umetsu M, et al. Adult-onset idiopathic hypogonadotropic hypogonadism due to isolated pituitary gonadotropin deficiency. Adv Intern Med. 2004;43(7):571-574.
Svartberg J, Aasebo U, Hjalmarsen A, et al. Testosterone treatment improves body composition and sexual function in men with COPD, in a 6-month randomized controlled trial. Respir Med. 2004;98(9):906-913. [pmid: 15338805].
Swartz DA, Todd MW. Intracavernous papaverine and glaucoma.[see comment]. JAMA. 1990;264(5):570. [pmid: 2366292].
Szucs A, Janszky J, Barsi P, et al. Sleep-related painful erection is associated with neurovascular compression of basal forebrain [5]. J Neurol. 2002;249(4):486-487. [pmid: 11967660].
T'Sjoen G, Feyen E, De Kuyper P, et al. Self-referred patients in an aging male clinic: much more than androgen deficiency alone. Aging Male. 2003;6(3):157-165. [pmid: 14628496].
Tam SW, Worcel M, Wyllie M. Yohimbine: a clinical review. [Review] [152 refs]. Pharmacol Ther. 2001;91(3):215-243. [pmid: 11744068].
Tarhan F, Canguven O, Kuyumcuoglu U. Intracavernous sodium nitroprusside (SNP) versus papaverine/phentolamine in erectile dysfunction: a comparative study of short-term efficacy and side-effects.[comment]. Br J Sex Med. 2006;3(2):377.
Tarhan F, Kuyumcuoglu U, Kolsuz A, et al. Effect of intracavernosal sodium nitroprusside in impotence. Urol Int. 1996;56(4):211-214. [pmid: 8776816].
Tas A, Dilek K, Gullulu M et al. Treatment of erectile dysfunction in hemodialysis patients and effects of sildenafil [abstract]. XXXVIII Congress of the European Renal Association European Dialysis & Transplant Association June 24–27 2003;2001, Vienna, Austria 131p. 2003.
Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005;88(3):241-254. [pmid: 16162361].
Teillac P, Bono AV, Irani J, et al. The role of luteinizing hormone-releasing hormone therapy in locally advanced prostate cancer and biochemical failure: Considerations for optimal use. Clin Ther. 2005;27(3):273-285. [pmid: 15878381].
Teloken PE, Smith EB, Lodowsky C, et al. Defining association between sleep apnea syndrome and erectile dysfunction. Urology. 2006;67(5):1033-1037. [pmid: 16698364].
Thadani U, Smith W, Nash S, et al. The effect of vardenafil, a potent and highly selective phosphodiesterase-5 inhibitor for the treatment of erectile dysfunction, on the cardiovascular response to exercise in patients with coronary artery disease. J Am Coll Cardiol. 2002;40(11):2006-2012. [pmid: 12475462].
Thaveundayil JX, Hambalek R, Ng Ying, et al. Prolonged penile erections induced by hydroxyzine: Possible mechanism of action. Neuropsychobiology. 1994;30(1):4-6. [pmid: 7969858].
Thrasher JB. What's new in urology. J Am Coll Surg. 2005;201(3):438-448. [pmid: 16125079].
Tindall B, Forde S, Goldstein D, et al. Sexual dysfunction in advanced HIV disease. AIDS Care. 1994;6(1):105-107. [pmid: 8186272].
Tomlinson J. Viagra and its use in cardiovascular disease.[erratum appears in J Hum Hypertens 2000 Apr;14(4):283]. [Review] [11 refs]. J Hum Hypertens. 1999;13(9):593-594. [pmid: 10482968].
Tomova A, Kumanov P. Are dehydroepiandrosterone sulphate and lipids associated with erectile dysfunction? [References]. Maturitas. 2005;50(4):294-299. [pmid: 15780529].
Tordjman G. NO/Pg E1: a new association in the treatment of erectile impotence. Contracept Fertil Sex (Paris) 1993;.21, pp.509–510, 1993.
Tosti A, Pazzaglia M, Soli M, et al. Evaluation of sexual function with an international index of erectile function in subjects taking finasteride for androgenetic alopecia.[see comment]. Arch Dermatol. 2004;140(7):857-858. [pmid: 15262698].
Traish AM, Goldstein I, Kim NN. Testosterone and erectile function: from basic research to a new clinical paradigm for managing men with androgen insufficiency and erectile dysfunction. Eur Urol. 2007;52(1):54-70. [pmid: 17329016].
Trinchieri A, Nicola M, Masini F, et al. Prospective comprehensive assessment of sexual function after retropubic non nerve sparing radical prostatectomy for localized prostate cancer. Arch Ital Urol Androl. 2005;77(4):219-223. [pmid: 16444937].
Truss MC, Becker AJ, Djamilian MH, et al. Role of the nitric oxide donor linsidomine chlorhydrate (SIN-1) in the diagnosis and treatment of erectile dysfunction. Urology. 1994;44(4):553-556. [pmid: 7941195].
Tsai SK, Hong CY. Intracavernosal metaraminol for treatment of intraoperative penile erection. Postgrad Med J. 1990;66(780):831-833. [pmid: 2099422].
Tsujimura A, Matsumiya K, Matsuoka Y, et al. Bioavailable testosterone with age and erectile dysfunction. Br J Urol. 2003;170(6 Pt 1):2345-2347.
Tuzgen S, Karamehmetoglu SS, Karacan I, et al. Use of sildenafil in the treatment of erectile dysfunction in patients with spinal cord injury. Neurosurgery Quarterly. 2006;16(1):40-43.
Tzivoni D, Klein J, Hisdai D, et al. The Israel Heart Society expert consensus document: The cardiac patient and sexual activity in the era of sildenafil (Viagra). Israel Medical Association Journal: Imaj. 2000;2(1):63-65. [pmid: 10892379].
Unnikrishnan AG, Rajaratnam S, Seshadri MS, et al. The ‘hook effect’ on serum prolactin estimation in a patient with macroprolactinoma. Neurol India. 2001;49(1):78-80. [pmid: 11303248].
Urciuoli R, Cantisani T A, CarliniI M et al. Prostaglandin E1 for treatment of erectile dysfunction. Cochrane Database Syst Rev 2004;(2):CD001784
Uygur MC, Arik AI, Altug U, et al. Effects of the 5 alpha-reductase inhibitor finasteride on serum levels of gonadal, adrenal, and hypophyseal hormones and its clinical significance: a prospective clinical study. Steroids. 1998;63(4):208-213. [pmid: 9589555].
Valdevenito R, Melman A. Intracavernous self-injection pharmacotherapy program: analysis of results and complications. Int J Impot Res. 1994;6(2):81-91. [pmid: 7951702].
van Basten JP, Van Driel MF, Hoekstra HJ, et al. Erectile dysfunction with chemotherapy.[comment]. Lancet. 2000;356(9224):169. [pmid: 10963279].
van Basten JP, Van Driel MF, Hoekstra HJ, et al. Erectile dysfunction with chemotherapy. Lancet. 2000;356(9224):169. [pmid: 10963279].
van Basten JP, Van Driel MF, Jonker-Pool G, et al. Sexual functioning in testosterone-supplemented patients treated for bilateral testicular cancer. Br J Urol. 1997;79(3):461-467. [pmid: 9117232].
Van Ahlen H, Peskar BA, Sticht G, et al. Pharmacokinetics of vasoactive substances administered into the human corpus cavernosum. Br J Urol. 1994;151(5):1227-1230.
Van Dijk M, Skrekas T, De La, et al. The association between lower urinary tract symptoms and sexual dysfunction: Fact or fiction?. Curr Opin Urol. 2005;15(1):39-44. [pmid: 15586029].
Van Moorselaar J. LUTS and Sexual Dysfunction: Implications for Management of BPH. European Urology Supplements. 2003;2(10):13-20.
Vardi M, Nini A. Phosphodiesterase inhibitors for erectile dysfunction in patients with diabetes mellitus. [Review][49 refs]. Cochrane Database Syst Rev 2007;(1):CD002187
Vatansever HS, Kayikcioglu O, Gumus B. Histopathologic effect of chronic use of sildenafil citrate on the choroid & retina in male rats. Indian J Med Res. 2003;117(MAY):211-215. [pmid: 14609049].
Verit A, Oguz H. Ophthalmic aspects of erectile dysfunction drugs [3]. Am J Ophthalmol. 2006;141(3):598. [pmid: 16490529].
Vick RN, Benevides M, Patel M, et al. The efficacy, safety and tolerability of intracavernous PNU-83757 for the treatment of erectile dysfunction. Br J Urol. 2002;167(6):2618-2623.
Vickers MA, De Nobrega AM, Dluhy RG. Diagnosis and treatment of psychogenic erectile dysfunction in a urological setting: Outcomes of 18 consecutive patients. Br J Urol. 1993;149(5 SUPPL.):1258-1261.
Vickers MA, Wright EA. Erectile dysfunction in the patient with diabetes mellitus. Am J Manag Care. 2004;10(1 SUPPL.):S3-S11. [pmid: 14974584].
Vidal J, Curcoll L, Roig T, et al. Intracavernous pharmacotherapy for management of erectile dysfunction in multiple sclerosis patients. Rev Neurol. 1995;23(120):269-271. [pmid: 7497173].
Vinik AI, Maser RE, Mitchell BD, et al. Diabetic autonomic neuropathy. [Review] [192 refs]. Diabetes Care. 2003;26(5):1553-1579. [pmid: 12716821].
Virag R. Intracavernous injection of papaverine for erectile failure. 1982. Br J Urol. 2002;167(2 Pt 2):1196.
Virag R, Floresco J, Richard C. Impairment of shear-stress-mediated vasodilation of cavernous arteries in erectile dysfunction. Int J Impot Res. 2004;16(1):39-42. [pmid: 14963469].
Vitezic D. A risk-benefit assessment of sildenafil in the treatment of erectile dysfunction. [Review] [72 refs]. Drug Saf. 2001;24(4):255-265. [pmid: 11330655].
Vlachopoulos C, Hirata K, O'Rourke MF. Effect of sildenafil on arterial stiffness and wave reflection. Vasc Med. 2003;8(4):243-248. [pmid: 15125484].
Vogt HJ, Brandl P, Kockott G, et al. Double-blind, placebo-controlled safety and efficacy trial with yohimbine hydrochloride in the treatment of nonorganic erectile dysfunction. Int J Impot Res. 1997;9(3):155-161. [pmid: 9315493].
Wagner G, Mulhall J. Pathophysiology and diagnosis of male erectile dysfunction. BJU International - Supplement. 2001;88(3):3-10.
Wagner G, Rabkin J, Rabkin R. Effects of testosterone replacement therapy on sexual interest, function, and behavior in HIV+ men. J Sex Res. 1997;34(1):27-33.
Wagner Gorm, Kaplan Helen, Singer. The new injection treatment for impotence: Medical and psychological aspects. Refuat Hapeh Vehashinayim 1993;x, 210 pp. Philadelphia, PA, US210
Wagrell L, Schelin S, Nordling J, et al. Three-year follow-up of feedback microwave thermotherapy versus TURP for clinical BPH: a prospective randomized multicenter study. Urology. 2004;64(4):698-702. [pmid: 15491704].
Wald M, Seftel AD, Ross LS, et al. Computational models for detection of erectile dysfunction. Br J Urol. 2005;173(1):167-170.
Waldbaum RS. The safety of PDE5 inhibitors in ED treatment: Putting cardiovascular concerns to rest. Cardiology Review. 2005;22(9):23-24.
Wang ZL, Shao SX, Li B, et al. Sildenafil versus prostaglandin E1 in the management of erectile dysfunction. Journal of Clinical Urology. 2002;17(7):347-349.
Wang Z, Liu BC, Chen B, et al. Randomized controlled study on erectile dysfunction treated by trazodone. Chinese Journal of Andrology. 2002;16(3):236-238.
Ware J, Catesby Rose F, Vincent McBrayer, et al. The acute effects of nefazodone, trazodone and buspirone on sleep and sleep-related penile tumescence in normal subjects. Sleep: Journal of Sleep Research & Sleep Medicine. 1994;17(6):544-550.
Watanabe T, Chancellor MB, Rivas DA, et al. Epidemiology of current treatment for sexual dysfunction in spinal cord injured men in the USA model spinal cord injury centers. J Spinal Cord Med. 1996;19(3):186-189. [pmid: 8819027].
Webb DJ, Freestone S, Allen MJ, et al. Sildenafil citrate and blood-pressure-lowering drugs: results of drug interaction studies with an organic nitrate and a calcium antagonist. Am J Cardiol. 1999;83(5A):21C-28C. [pmid: 10073779].
Webb DJ, Muirhead GJ, Wulff M, et al. Sildenafil citrate potentiates the hypotensive effects of nitric oxide donor drugs in male patients with stable angina. J Am Coll Cardiol. 2000;36(1):25-31. [pmid: 10898408].
Wegner HEH, Knispel HH, Meier T, et al. Nitric oxide donor, linsidomine chlorhydrate (SIN-1), in the diagnosis and treatment of erectile dysfunction: Critical appraisal and review of the literature. International Urology & Nephrology. 1995;27(5):621-628. [pmid: 8775048].
Weinhardt LS, Carey MP. Prevalence of erectile disorder among men with diabetes mellitus: Comprehensive review, methodological critique, and suggestions for future research. J Sex Res. 1996;33(3):205-214.
Weinsaft JW, Hickey K, Bokhari S, et al. Effects of tadalafil on myocardial blood flow in patients with coronary artery disease. Coron Artery Dis. 2006;17(6):493-499. [pmid: 16905960].
Weiske WH. Invasive diagnosis and therapy - Are they still reasonable in the age of sildenafil?. Andrologia. 1999;31(SUPPL. 1):95-97. [pmid: 10643526].
Wespes E, Rammal A, Garbar C. Sildenafil non-responders: haemodynamic and morphometric studies. Eur Urol. 2005;48(1):136-139. [pmid: 15967263].
Wessells H, Fuciarelli K, Hansen J, et al. Synthetic melanotropic peptide initiates erections in men with psychogenic erectile dysfunction: double-blind, placebo controlled crossover study. Br J Urol. 1998;160(2):389-393.
Wessells H, Gralnek D, Dorr R, et al. Effect of an alpha-melanocyte stimulating hormone analog on penile erection and sexual desire in men with organic erectile dysfunction. Urology. 2000;56(4):641-646. [pmid: 11018622].
Wheatley D. Triple-blind, placebo-controlled trial of Ginkgo biloba in sexual dysfunction due to antidepressant drugs. Hum Psychopharmacol. 2004;19(8):545-548. [pmid: 15378664].
Wilke DR, Parker C, Andonowski A, et al. Testosterone and erectile function recovery after radiotherapy and long-term androgen deprivation with luteinizing hormone-releasing hormone agonists. BJU Int. 2006;97(5):963-968. [pmid: 16542340].
Williams G. Male erectile dysfunction. Prescribers' Journal. 2000;40(1):49-58.
Williams T, Honeywell M, Branch E et al. Tadalafil in the treatment of erectile dysfunction. P & T 2004;29(5):
Wilt TJ, Fink HA. Is antidepressant plus sildenafil a recipe for priapism?. Postgrad Med. 2004;116(6):11-12. [pmid: 15620123].
Witt Deborah K. Yohimbine for erectile dysfunction. J Fam Pract. 1998;46(4):282-283. [pmid: 9564368].
Wood P L. Slow, tedious but essential: The need for incremental R&D. Current Drug Discovery 2004;(pp 31–35):-35.
Wyllie MG. The hunt for pink Viagra. BJU Int. 2005;95(1):181-182. [pmid: 15638919].
Wyllie MG. Let's hope for more in 2004. BJU Int. 2004;93(1):175-176. [pmid: 14678392].
Wyllie MG. The Second International Consultation on Erectile Dysfunction: Highlights from the pharmaceutical industry. BJU Int. 2003;92(6):645-646. [pmid: 14511053].
Wyllie MG. The genesis of a phytopharmaceutical industry (Mark II). BJU Int. 2003;91(7):721-722. [pmid: 12699492].
Yajima T, Yajima Y, Koppiker N, et al. No clinically important effects on intraocular pressure after short-term administration of sildenafil citrate (Viagra). Am J Ophthalmol. 2000;129(5):675-676. [pmid: 10844068].
Yaman O, Akand M, Gursoy A, et al. The effect of diabetes mellitus treatment and good glycemic control on the erectile function in men with diabetes mellitus-induced erectile dysfunction: a pilot study. Br J Sex Med. 2006;3(2):344-348.
Yaman O, Tokatli Z, Akand M, et al. Characteristics of sildenafil erections in healthy young men. Asian J Androl. 2005;7(4):395-398. [pmid: 16281087].
Yamanaka M, Shirai M, Shiina H, et al. Vascular endothelial growth factor restores erectile function through inhibition of apoptosis in diabetic rat penile crura. Br J Urol. 2005;173(1):318-323.
Yan JY, Yang WZ. A comparative effects of Sildenafil and Yohimbine for the treatment of erectile dysfunction. Chinese Journal of Andrology. 2000;14(2):103-105.
Yarkony GM. Enhancement of sexual function and fertility in spinal cord-injured males. [Review] [40 refs]. Am J Phys Med Rehabil. 1990;69(2):81-87. [pmid: 2184843].
Yassin AA, Saad F. Treatment of sexual dysfunction of hypogonadal patients with long-acting testosterone undecanoate (Nebido). [Review] [25 refs]. World J Urol. 2006;24(6):639-644. [pmid: 17048032].
Yassin AA, Saad F. Dramatic improvement of penile venous leakage upon testosterone administration. A case report and review of literature. Andrologia. 2006;38(1):34-37. [pmid: 16420241].
Yasumoto R, Nishisaka N, Sakakura T, et al. Ethanol embolization for impotent patients with venous leakage: A new technique and initial results. Minimally Invasive Therapy & Allied Technologies: Mitat. 1996;5(6):564-566.
Yeager J, Beihn RM. Retention and migration of alprostadil cream applied topically to the glans meatus for erectile dysfunction. Int J Impot Res. 2005;17(1):91-95. [pmid: 15538395].
Youssef AF, Fort FL, Ronsen B, et al. Evaluation of apomorphine HCl effects on reproductive endpoints: Studies in male rats and dogs. J Toxicol Sci. 1999;51(2):273-279.
Zaslau S, Nicolis C, Galea G, et al. A simplified pharmacologic erection program for patients with spinal cord injury. J Spinal Cord Med. 1999;22(4):303-307. [pmid: 10751135].
Zasler ND. Therapeutic approaches to sexual impotence. Hospital Practice (Office Edition). 1988;23(7):197-200.
Zhao L. Clinical observation on the therapeutic effects of heavy moxibustion plus point-injection in treatment of impotence. J Tradit Chin Med. 2004;24(2):126-127. [pmid: 15270266].
Zhigang Long, Xiaowei Liu, Shengbo Lu. Therapy of impotence with traditional Chinese medicine. Journal of Sex Education & Therapy. 1994;20(2):140-143.
Ziegler D. Management of erectile dysfunction in diabetic patients. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):58-65.
Zini Dante, Carani Cesare, Baldini Augusto, et al. Sexual behavior of men with isolated hypogonadotropic hypogonadism or prepubertal anterior panhypopituitarism. Horm Behav. 1990;24(2):174-185. [pmid: 2365300].
Zlotta AR, Teillac P, Raynaud JP, et al. Evaluation of male sexual function in patients with Lower Urinary Tract Symptoms (LUTS) associated with Benign Prostatic Hyperplasia (BPH) treated with a phytotherapeutic agent (Permixon), Tamsulosin or Finasteride. Eur Urol. 2005;48(2):269-276. [pmid: 15939527].
Zusman RM. Cardiovascular data on sildenafil citrate: introduction.[erratum appears in Am J Cardiol 1999 Jul 15;84(2):244]. Am J Cardiol. 1999;83(5A):1C-2C. [pmid: 10073775].
Zusman RM, Morales A, Glasser DB, et al. Overall cardiovascular profile of sildenafil citrate. [Review] [33 refs]. Am J Cardiol. 1999;83(5A):35C-44C.
Zusman RM, Prisant LM, Brown MJ. Effect of sildenafil citrate on blood pressure and heart rate in men with erectile dysfunction taking concomitant antihypertensive medication. Sildenafil Study Group. J Hypertens. 2000;18(12):1865-1869. [pmid: 11132612].

## Observational injection study with < 6 months followup in duration

Bancroft J, Smith G, Munoz M, et al. Erectile response to visual erotic stimuli before and after intracavernosal papaverine, and its relationship to nocturnal penile tumescence and psychometric assessment. Br J Urol. 1991;68(6):629-638. [pmid: 1773296].
Beretta G, Marzotto M, Zanollo A, et al. Office treatment: intracavernous injections of prostaglandin E1 (PG E1) and improvement of spontaneous erections. Acta Eur Fertil. 1991;22(4):221-223. [pmid: 1844326].
Bird TD, Lipe HP, Crabtree LD. Impotence associated with the Charcot-Marie-Tooth syndrome. Eur Neurol. 1994;34(3):155-157. [pmid: 8033941].
Brown SL, Haas CA, Koehler M, et al. Hepatotoxicity related to intracavernous pharmacotherapy with papaverine. Urology. 1998;52(5):844-847. [pmid: 9801111].
Casella R, Deckart A, Bachmann A, et al. The patient's self-evaluation better predicts the degree of erectile dysfunction than the response to intracavernous alprostadil testing. Urol Int. 2004;72(3):216-220. [pmid: 15084765].
Chatterjee R, Kottaridis PD, McGarrigle HH, et al. Management of erectile dysfunction by combination therapy with testosterone and sildenafil in recipients of high-dose therapy for haematological malignancies. Bone Marrow Transplant. 2002;29(7):607-610. [pmid: 11979311].
Chun SS, Fenemore J, Heaton JP, et al. Enhancement of erectile responses to vasoactive drugs by a variable amplitude oscillation device. Int J Impot Res. 1996;8(4):221-225. [pmid: 8981171].
Dinsmore WW, Alderdice DK. Vasoactive intestinal polypeptide and phentolamine mesylate administered by autoinjector in the treatment of patients with erectile dysfunction resistant to other intracavernosal agents. Br J Urol. 1998;81(3):437-440. [pmid: 9523666].
Fein RL. Classification of sexual dysfunction for management of intracavernous medication-induced erections.[see comment]. Br J Urol. 1990;143(2):298-301.
Goonawardena SA, de Silva WA, Ketheeswaran T. Pharmacologically induced penile erections in the assessment and treatment of erectile impotence: a preliminary study of 100 patients. Ceylon Med J. 1997;42(2):72-74. [pmid: 9257465].
Greco E, Balbi PP, Virag R. Self intra-cavernous injections as a successful treatment in pure neurogenic impotence. Riv Neurol. 1991;61(1):35-38. [pmid: 1857921].
Kadioglu A, Erdogru T, Tellaloglu S. Combined intracavernous injection of papaverine and stimulation (CIS) test. J Androl. 1994;15(Suppl):50S-53S. [pmid: 7721678].
Katlowitz NM, Albano GJ, Morales P, et al. Potentiation of drug-induced erection with audiovisual sexual stimulation. Urology. 1993;41(5):431-434. [pmid: 8488610].
Katlowitz N, Albano GJ, Patsias G, et al. Effect of multidose intracorporeal injection and audiovisual sexual stimulation in vasculogenic impotence. Urology. 1993;42(6):695-697. [pmid: 8256402].
Kim JM, Joh YD, Huh JD, et al. Doppler sonography of the penile cavernosal artery: comparison of intraurethral instillation and intracorporeal injection of prostaglandin E1. J Clin Ultrasound. 2001;29(5):273-278. [pmid: 11486321].
Knispel HH. Penile venous surgery in impotence: results in highly selected cases. Urol Int. 1991;47(3):144-148. [pmid: 1771702].
Kromann-Andersen B. Intracavernosal pharmacotherapy with injection pen. Lancet. 1988;1(85756):54-59. [pmid: 2891913].
Mansi MK, Alkhudair WK, Huraib S. Treatment of erectile dysfunction after kidney transplantation with intracavernosal self-injection of prostaglandin E1. Br J Urol. 1998;159(6):1927-1930.
McMahon CG. A pilot study of the role of intracavernous injection of vasoactive intestinal peptide (VIP) and phentolamine mesylate in the treatment of erectile dysfunction. Int J Impot Res. 1996;8(4):233-236. [pmid: 8981173].
McMahon CG. Priapism associated with concurrent use of phosphodiesterase inhibitor drugs and intracavernous injection therapy. Int J Impot Res. 2003;15(5):383-384. [pmid: 14562142].
Metawea B, El-Nashar AR, Gad-Allah A, et al. Intracavernous papaverine/phentolamine-induced priapism can be accurately predicted with color Doppler ultrasonography. Urology. 2005;66(4):858-860. [pmid: 16230153].
Mirone V, Imbimbo C, Fabrizio F, et al. Ketanserin plus prostaglandin E1 (PGE-1) as intracavernosal therapy for patients with erectile dysfunction unresponsive to PGE-1 alone. Br J Urol. 1996;77(5):736-739. [pmid: 8689122].
Nagai A, Kusumi N, Tsuboi H, et al. Intracavernous injection of prostaglandin E1 is effective in patients with erectile dysfunction not responding to phosphodiseterase 5 inhibitors. Acta Med Okayama. 2005;59(6):279-280. [pmid: 16418771].
Nalesnik JG, Jones L, Kraus SR. Group B streptococcal septicemia following intracavernous injection therapy for erectile dysfunction in diabetes. Br J Urol. 2004;172(1):151-152.
Pagani E, Puech-Leao P, Glina S, et al. The value of a second injection on the pharmaco-induced erection test. Int J Impot Res. 1997;9(3):167-168. [pmid: 9315495].
Price DE, Cooksey G, Jehu D, et al. The management of impotence in diabetic men by vacuum tumescence therapy. Diabet Med. 1991;8(10):964-967. [pmid: 1838050].
Rodilla F, Fuentes MD, Chuan P, et al. Penile self-injection for impotence in patients after radical cystectomy. Journal of Clinical Pharmacy & Therapeutics. 1994;19(6):359-360. [pmid: 7876367].
Rodrigues M, Granegger S, O'Grady J, et al. Accumulation of platelets as a key mechanism of human erection. A scintigraphic study in patients with erectile dysfunction receiving intracavernous injection of PGE1, papaverine/phentolamine. Advances in Experimental Medicine & Biology. 1997;43:379-82.
Schouman M, Lacroix P, Amer M. Suppression of prostaglandin E1-induced pain by dilution of the drug with lidocaine before intracavernous injection. Br J Urol. 1992;148(4):1266.
Sparwasser C, Treiber U, Bahren W, et al. Postoperative erectile dysfunction; evaluation and treatment with intracavernous vasoactive injections. Progress in Clinical & Biological Research. 1991;370:349-354. [pmid: 1924468].
Stief CG, Holmquist F, Djamilian M, et al. Preliminary results with the nitric oxide donor linsidomine chlorhydrate in the treatment of human erectile dysfunction. Br J Urol. 1992;148(5):1437-1440.
Stief CG, Wetterauer U, Schaebsdau FH, et al. Calcitonin-gene-related peptide: a possible role in human penile erection and its therapeutic application in impotent patients. Br J Urol. 1991;146(4):1010-1014.
Vickers MA, De Nobrega AM, Dluhy RG. Diagnosis and treatment of psychogenic erectile dysfunction in a urological setting: Outcomes of 18 consecutive patients. Br J Urol. 1993;149(5 SUPPL.):1258-1261.
Weiss JN, Ravalli R, Badlani GH. Intracavernous pharmacotherapy in psychogenic impotence. Urology. 1991;37(5):441-443. [pmid: 1708925].

## Observational injection study > or = to 6 months in duration

al-Juburi AZ, O'Donnell PD. Follow up outcome of intracavernous papaverine. J Ark Med Soc. 1990;86(10):383-385. [pmid: 2138146].
Armstrong DK, Convery AG, Dinsmore WW. Reasons for patient drop-out from an intracavernous auto-injection programme for erectile dysfunction. Br J Urol. 1994;74(1):99-101. [pmid: 8044533].
Chang DW, Wood CG, Kroll SS, et al. Cavernous nerve reconstruction to preserve erectile function following non-nerve-sparing radical retropubic prostatectomy: a prospective study. Keisei Geka. 2003;111(3):1174-1181.
Chen J, Godschalk MF, Katz PG, et al. Incidence of penile pain after injection of a new formulation of prostaglandin E1.[see comment]. Br J Urol. 1995;154(1):77-79.
Chen J, Godschalk MF, Katz PG, et al. Combining intracavernous injection and external vacuum as treatment for erectile dysfunction.[see comment]. Br J Urol. 1995;153(5):1476-1477.
Cooper AJ. Evaluation of I-C papaverine in patients with psychogenic and organic impotence. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 1991;36(8):574-578. [pmid: 1742710].
Dhabuwala CB, Kerkar P, Bhutwala A, et al. Intracavernous papaverine in the management of psychogenic impotence. Arch Androl. 1990;24(2):185-191. [pmid: 2327828].
Fedele D, Coscelli C, Cucinotta D, et al. Management of erectile dysfunction in diabetic subjects: results from a survey of 400 diabetes centres in Italy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14(5):277-282.
Fein RL. Classification of sexual dysfunction for management of intracavernous medication-induced erections.[see comment]. Br J Urol. 1990;143(2):298-301.
Fugl-Meyer AR, Lodnert G, Branholm IB, et al. On life satisfaction in male erectile dysfunction. Int J Impot Res. 1997;9(3):141-148. [pmid: 9315491].
Godschalk M, Gheorghiu D, Chen J, et al. Long-term efficacy of a new formulation of prostaglandin E1 as treatment for erectile failure. Br J Urol. 1996;155(3):915-917.
Govier FE, McClure RD, Weissman RM, et al. Experience with triple-drug therapy in a pharmacological erection program.[see comment]. Br J Urol. 1993;150(6):1822-1824.
Incrocci L, Hop WC, Slob AK. Visual erotic and vibrotactile stimulation and intracavernous injection in screening men with erectile dysfunction: a 3 year experience with 406 cases. Int J Impot Res. 1996;8(4):227-232. [pmid: 8981172].
Irwin MB, Kata EJ. High attrition rate with intracavernous injection of prostaglandin E1 for impotency. Urology. 1994;43(1):84-87. [pmid: 8284888].
Jiann BP, Yu CC, Su CC. Impact of introduction of sildenafil on other treatment modalities for erectile dysfunction: A study of nationwide and local hospital sales. Int J Impot Res. 2004;16(6):527-530. [pmid: 15229626].
Kattan SA. The acceptance of satisfaction of Saudi males to vasoactive autoinjection intracavernous therapy, external negative pressure device and penile prosthesis in the treatment of erectile dysfunction. Ann Saudi Med. 2002;22(34):149-152. [pmid: 17159384].
Knispel HH, Huland H. Influence of cause on choice of therapy in 174 patients with erectile dysfunction. Br J Urol. 1992;147(5):1274-1276.
Lim PH, Ng FC. Erectile dysfunction in Singapore men: presentation, diagnosis, treatment and results. Ann Acad Med Singapore. 1992;21(2):248-253. [pmid: 1519896].
Lottman PE, Hendriks JC, Vruggink PA, et al. The impact of marital satisfaction and psychological counselling on the outcome of ICI-treatment in men with ED. Int J Impot Res. 1998;10(2):83-87. [pmid: 9647943].
Lundberg L, Olsson JO, Kihl B. Long-term experience of self-injection therapy with prostaglandin E1 for erectile dysfunction. Scand J Urol Nephrol. 1996;30(5):395-397. [pmid: 8936629].
Maniam P, Seftel AD, Corty EW, et al. Nocturnal penile tumescence activity unchanged after long-term intracavernous injection therapy. Br J Urol. 2001;165(3):830-832.
Mark SD, Keane TE, Vandemark RM, et al. Impotence following pelvic fracture urethral injury: incidence, aetiology and management. Br J Urol. 1995;75(1):62-64. [pmid: 7850299].
Montorsi F, Guazzoni G, Bergamaschi F, et al. Effectiveness and safety of multidrug intracavernous therapy for vasculogenic impotence. Urology. 1993;42(5):554-558. [pmid: 7694416].
Montorsi F, Guazzoni G, Bergamaschi F, et al. Four-drug intracavernous therapy for impotence due to corporeal veno-occlusive dysfunction. Br J Urol. 1993;149(5 Pt 2):1291-1295.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Intracavernous vasoactive pharmacotherapy: the impact of a new self-injection device.[see comment]. Br J Urol. 1993;150(6):1829-1832.
Mulhall JP, Jahoda AE, Cairney M, et al. The causes of patient dropout from penile self-injection therapy for impotence. Br J Urol. 1999;162(4):1291-1294.
Mulhall JP, Land S, Parker M, et al. The use of an erectogenic pharmacotheraphy regimen following radical prostatectomy improves recovery of spontaneous erectile function. Br J Sex Med. 2005;2(4):532-542.
Perimenis P, Athanasopoulos A, Geramoutsos I, et al. The incidence of pharmacologically induced priapism in the diagnostic and therapeutic management of 685 men with erectile dysfunction. Urol Int. 2001;66(1):27-29. [pmid: 11150947].
Rowland DL, Boedhoe HSM, Dohle G, et al. Intracavernosal self-injection therapy in men with erectile dysfunction: Satisfaction and attrition in 119 patients. Int J Impot Res. 1999;11(3):145-151. [pmid: 10404283].
Sparwasser C, Treiber U, Bahren W, et al. Postoperative erectile dysfunction; evaluation and treatment with intracavernous vasoactive injections. Progress in Clinical & Biological Research. 1991;370:349-354. [pmid: 1924468].
Speckens AE, Kattemolle MR, Hengeveld MW, et al. A prospective long-term follow-up study of patients evaluated for erectile dysfunction: outcome and associated factors. Int J Impot Res. 1995;7(2):101-110. [pmid: 7496438].
Tariq SH, Haleem U, Omran ML, et al. Erectile dysfunction: Etiology and treatment in young and old patients. Clin Geriatr Med. 2003;19(3):539-551. [pmid: 14567006].
Turner LA, Althof SE. The clinical effectiveness of self-injection and external vacuum devices in the treatment of erectile dysfunction: a six-month comparison. Psychiatr Med. 1992;10(2):283-293. [pmid: 1377397].
Virag R. Intracavernous injection of papaverine for erectile failure. 1982. Br J Urol. 2002;167(2 Pt 2):1196.
Weidner W, Schroeder-Printzen I, Fischer C, et al. Experience in the treatment of erectile dysfunction using the intracavernosal self-injection of papaverine: Results of a prospective study after a median follow-up of 42 months involving 135 patients and 10766 injections. World J Urol. 1992;10(3):179-182.
Weiss JN, Badlani GH, Ravalli R, et al. Reasons for high drop-out rate with self-injection therapy for impotence. Int J Impot Res. 1994;6(3):171-174. [pmid: 7735362].

## Not relevant by study design

Allan CA, McLachlan RI. Age-related changes in testosterone and the role of replacement therapy in older men. Clin Endocrinol (Oxf). 2004;60(6):653-670. [pmid: 15163327].
Anderson DC, Seifert CF. Topical nitrate treatment of impotence. [Review] [17 refs]. Ann Pharmacother. 1993;27(10):1203-1205. [pmid: 8251690].
Anonymous. Sildenafil for erectile dysfunction. Drug Ther.Bull 1998;36(11):81–84.
Anonymous. Vardenafil (levitra) for erectile dysfunction. Medical Letter on Drugs & Therapeutics 2003;45(1166):77–78.
Anonymous. Vasoactive intestinal peptide/phentolamine. Invicorp, vasopotin. Drugs in R & D 1999;2(6):436–438.
Berner M M, Kriston L, Harms A. Efficacy of PDE-5-inhibitors for erectile dysfunction. A comparative meta-analysis of fixed-dose regimen randomized controlled trials administering the International Index of Erectile Function in broad-spectrum populations. Int J Impot Res 2005;
Blanker MH, Thomas S, Bohnen AM. Systematic review of Viagra RCTs. Br J Gen Pract. 2002;52(477):329. [pmid: 11942454].
Bolona ER, Uraga MV, Haddad RM, et al. Testosterone use in men with sexual dysfunction: a systematic review and meta-analysis of randomized placebo-controlled trials. Mayo Clin Proc. 2007;82(1):20-28. [pmid: 17285782].
Burls A, Gold L, Clark W. Systematic review of randomised controlled trials of sildenafil (Viagra) in the treatment of male erectile dysfunction. Br J Gen Pract. 2001;51(473):1004-1012. [pmid: 11766850].
Calof OM, Singh AB, Lee ML, et al. Adverse events associated with testosterone replacement in middle-aged and older men: A meta-analysis of randomized, placebo-controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60(11):1451-1457.
Carey MP, Johnson BT. Effectiveness of yohimbine in the treatment of erectile disorder: four meta-analytic integrations. Arch Sex Behav. 1996;25(4):341-360. [pmid: 8836468].
Carson CC, Burnett AL, Levine LA, et al. The efficacy of sildenafil citrate (Viagra) in clinical populations: an update. Urology. 2002;60(2 Suppl 2):12-27. [pmid: 12414330].
Chen CT, Valicenti RK, Lu J, et al. Does hormonal therapy influence sexual function in men receiving 3D conformal radiation therapy for prostate cancer?. Int J Radiat Oncol Biol Phys. 2001;50(3):591-595. [pmid: 11395224].
Chiang HS, Kao YH, Sheu MT. Papaverine and prostaglandin E1 gel applications for impotence. Ann Acad Med Singapore. 1995;24(5):767-769. [pmid: 8579329].
Crowe SM, Streetman DS. Vardenafil treatment for erectile dysfunction. [Review] [43 refs]. Ann Pharmacother. 2004;38(1):77-85. [pmid: 14742800].
Derry F, Hultling C, Seftel AD, et al. Efficacy and safety of sildenafil citrate (Viagra) in men with erectile dysfunction and spinal cord injury: a review. Urology. 2002;60(2 Suppl 2):49-57. [pmid: 12414333].
Ernst E, Pittler MH. Yohimbine for erectile dysfunction: a systematic review and meta-analysis of randomized clinical trials. J Urol. 1998;159(2):433-436. [pmid: 9649257].
Escobar-Jimenez F. [Efficacy and safety of sildenafil in men with type 2 diabetes mellitus and erectile dysfunction]. Med Clin (Barc). 2002;119(4):121-124. [pmid: 12106522].
Fink HA, Mac Donald R, Rutks IR, et al. Sildenafil for male erectile dysfunction: a systematic review and meta-analysis. Arch Intern Med. 2002;162(12):1349-1360. [pmid: 12076233].
Fink HA, MacDonald R, Rutks IR, et al. Trazodone for erectile dysfunction: a systematic review and meta-analysis. BJU Int. 2003;92(4):441-446. [pmid: 12930437].
Hellstrom WJ. Vardenafil: a new approach to the treatment of erectile dysfunction. [Review] [37 refs]. Curr Urol Rep. 2003;4(6):479-487. [pmid: 14622502].
Holmes S. Tadalafil: a new treatment for erectile dysfunction. BJU Int. 2003;91(6):466-468. [pmid: 12656894].
Isidori AM, Giannetta E, Gianfrilli D, et al. Effects of testosterone on sexual function in men: results of a meta-analysis. Clin Endocrinol (Oxf). 2005;63(4):381-394. [pmid: 16181230].
Jain P, Rademaker AW, McVary KT. Testosterone supplementation for erectile dysfunction: results of a meta-analysis. Br J Urol. 2000;164(2):371-375.
Keating GM, Scott LJ. Vardenafil: a review of its use in erectile dysfunction. Drugs. 2003;63(23):2673-2703. [pmid: 14636086].
Keating GM, Scott LJ. Spotlight on vardenafil in erectile dysfunction. Drugs Aging. 2004;21(2):135-140. [pmid: 14960129].
Kloner RA. Cardiovascular effects of the 3 phosphodiesterase-5 inhibitors approved for the treatment of erectile dysfunction. [Review] [57 refs]. Circulation. 2004;110(19):3149-3155. [pmid: 15533876].
Langtry HD, Markham A. Sildenafil: a review of its use in erectile dysfunction. Drugs. 1999;57(6):967-989. [pmid: 10400408].
Lewis RW. Intraurethral and topical agents. Med Actual. 2000;36(23):113-119.
Licht M R, Schover L R. Sildenafil (Viagra) for treating male erectile dysfunction. Cleve Clin J Med 1998;65(6):
Markou S, Perimenis P, Gyftopoulos K, et al. Vardenafil (Levitra) for erectile dysfunction: a systematic review and meta-analysis of clinical trial reports. Int J Impot Res. 2004;16(6):470-478. [pmid: 15229625].
McMahon CG. Topiglan: MacroChem. Curr Opin Investig Drugs. 2002;3(4):602-606.
Mikhail N. Does Testosterone Have a Role in Erectile Function?. Am J Med. 2006;119:373-382. [pmid: 16651047].
Montorsi F, McCullough A. Efficacy of sildenafil citrate in men with erectile dysfunction following radical prostatectomy: A systematic review of clinical data. Br J Sex Med. 2005;2(5):658-667.
Moore R A, Derry S, McQuay H J. Indirect comparison of interventions using published randomised trials: systematic review of PDE-5 inhibitors for erectile dysfunction. [Review][77 refs]. BMC Urol 2005;518
Moore R A, Edwards J E, McQuay H J. Sildenafil (Viagra) for male erectile dysfunction: a meta-analysis of clinical trial reports. BMC Urol. 2002;26
Morales A, Gingell C, Collins M, et al. Clinical safety of oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):69-73. [pmid: 9647940].
Padma-Nathan H, Eardley I, Kloner RA, et al. A 4-year update on the safety of sildenafil citrate (Viagra). [Review] [88 refs]. Urology. 2002;60(2:Suppl 2):Suppl-90.
Rashid A. The efficacy and safety of PDE5 inhibitors. [Review] [30 refs]. Clin Cornerstone. 2005;7(1):47-56. [pmid: 16156423].
Rudkin L, Taylor M J, Hawton K. Strategies for managing sexual dysfunction induced by antidepressant medication. [Review][61 refs]. Cochrane Database Syst Rev 2004;(4):CD003382
Setter SM, Iltz JL, Fincham JE, et al. Phosphodiesterase 5 inhibitors for erectile dysfunction. [Review] [75 refs]. Ann Pharmacother. 2005;39(78):1286-1295. [pmid: 15941818].
Sommer F, Engelmann U. Vardenafil: Bayer Yakuhin. Curr Opin Investig Drugs. 2002;3(4):607-613.
Sternbach Harvey. Age-associated testosterone decline in men: Clinical issues for psychiatry. Am J Psychiatry. 1998;155(10):1310-1318. [pmid: 9766760].
Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005;88(3):241-254. [pmid: 16162361].
Tomsak R. PDE5 inhibitors and permanent visual loss. Int J Impot Res. 2005;17(6):547-549. [pmid: 16193072].
Tran D, Howes LG. Cardiovascular safety of sildenafil. Drug Saf. 2003;26(7):453-460. [pmid: 12735784].
Urciuoli R, Cantisani T A, CarliniI M et al. Prostaglandin E1 for treatment of erectile dysfunction. Cochrane Database Syst Rev 2004;(2):CD001784
Uygur MC, Arik AI, Altug U, et al. Effects of the 5 alpha-reductase inhibitor finasteride on serum levels of gonadal, adrenal, and hypophyseal hormones and its clinical significance: a prospective clinical study. Steroids. 1998;63(4):208-213. [pmid: 9589555].
Valdevenito R, Melman A. Intracavernous self-injection pharmacotherapy program: analysis of results and complications. Int J Impot Res. 1994;6(2):81-91. [pmid: 7951702].
van Basten JP, Van Driel MF, Hoekstra HJ, et al. Erectile dysfunction with chemotherapy.[comment]. Lancet. 2000;356(9224):169. [pmid: 10963279].
van Basten JP, Van Driel MF, Hoekstra HJ, et al. Erectile dysfunction with chemotherapy. Lancet. 2000;356(9224):169. [pmid: 10963279].
van Basten JP, Van Driel MF, Jonker-Pool G, et al. Sexual functioning in testosterone-supplemented patients treated for bilateral testicular cancer. Br J Urol. 1997;79(3):461-467. [pmid: 9117232].
Van Ahlen H, Peskar BA, Sticht G, et al. Pharmacokinetics of vasoactive substances administered into the human corpus cavernosum. Br J Urol. 1994;151(5):1227-1230.
Van Dijk M, Skrekas T, De La, et al. The association between lower urinary tract symptoms and sexual dysfunction: Fact or fiction?. Curr Opin Urol. 2005;15(1):39-44. [pmid: 15586029].
Van Moorselaar J. LUTS and Sexual Dysfunction: Implications for Management of BPH. European Urology Supplements. 2003;2(10):13-20.
Vardi M, Nini A. Phosphodiesterase inhibitors for erectile dysfunction in patients with diabetes mellitus. [Review][49 refs]. Cochrane Database Syst Rev 2007;(1):CD002187
Vatansever HS, Kayikcioglu O, Gumus B. Histopathologic effect of chronic use of sildenafil citrate on the choroid & retina in male rats. Indian J Med Res. 2003;117(MAY):211-215. [pmid: 14609049].
Verit A, Oguz H. Ophthalmic aspects of erectile dysfunction drugs [3]. Am J Ophthalmol. 2006;141(3):598. [pmid: 16490529].
Vick RN, Benevides M, Patel M, et al. The efficacy, safety and tolerability of intracavernous PNU-83757 for the treatment of erectile dysfunction. Br J Urol. 2002;167(6):2618-2623.
Vickers MA, De Nobrega AM, Dluhy RG. Diagnosis and treatment of psychogenic erectile dysfunction in a urological setting: Outcomes of 18 consecutive patients. Br J Urol. 1993;149(5 SUPPL.):1258-1261.
Vickers MA, Wright EA. Erectile dysfunction in the patient with diabetes mellitus. Am J Manag Care. 2004;10(1 SUPPL.):S3-S11. [pmid: 14974584].
Vidal J, Curcoll L, Roig T, et al. Intracavernous pharmacotherapy for management of erectile dysfunction in multiple sclerosis patients. Rev Neurol. 1995;23(120):269-271. [pmid: 7497173].
Vinik AI, Maser RE, Mitchell BD, et al. Diabetic autonomic neuropathy. [Review] [192 refs]. Diabetes Care. 2003;26(5):1553-1579. [pmid: 12716821].
Virag R. Intracavernous injection of papaverine for erectile failure. 1982. Br J Urol. 2002;167(2 Pt 2):1196.
Virag R, Floresco J, Richard C. Impairment of shear-stress-mediated vasodilation of cavernous arteries in erectile dysfunction. Int J Impot Res. 2004;16(1):39-42. [pmid: 14963469].
Vitezic D. A risk-benefit assessment of sildenafil in the treatment of erectile dysfunction. [Review] [72 refs]. Drug Saf. 2001;24(4):255-265. [pmid: 11330655].
Vlachopoulos C, Hirata K, O'Rourke MF. Effect of sildenafil on arterial stiffness and wave reflection. Vasc Med. 2003;8(4):243-248. [pmid: 15125484].
Vogt HJ, Brandl P, Kockott G, et al. Double-blind, placebo-controlled safety and efficacy trial with yohimbine hydrochloride in the treatment of nonorganic erectile dysfunction. Int J Impot Res. 1997;9(3):155-161. [pmid: 9315493].
Wagner G, Mulhall J. Pathophysiology and diagnosis of male erectile dysfunction. BJU International - Supplement. 2001;88(3):3-10.
Wagner G, Rabkin J, Rabkin R. Effects of testosterone replacement therapy on sexual interest, function, and behavior in HIV+ men. J Sex Res. 1997;34(1):27-33.
Wagner Gorm, Kaplan Helen, Singer. The new injection treatment for impotence: Medical and psychological aspects. Refuat Hapeh Vehashinayim 1993;x, 210 pp. Philadelphia, PA, US210
Wagrell L, Schelin S, Nordling J, et al. Three-year follow-up of feedback microwave thermotherapy versus TURP for clinical BPH: a prospective randomized multicenter study. Urology. 2004;64(4):698-702. [pmid: 15491704].
Wald M, Seftel AD, Ross LS, et al. Computational models for detection of erectile dysfunction. Br J Urol. 2005;173(1):167-170.
Waldbaum RS. The safety of PDE5 inhibitors in ED treatment: Putting cardiovascular concerns to rest. Cardiology Review. 2005;22(9):23-24.
Wang ZL, Shao SX, Li B, et al. Sildenafil versus prostaglandin E1 in the management of erectile dysfunction. Journal of Clinical Urology. 2002;17(7):347-349.
Wang Z, Liu BC, Chen B, et al. Randomized controlled study on erectile dysfunction treated by trazodone. Chinese Journal of Andrology. 2002;16(3):236-238.
Ware J, Catesby Rose F, Vincent McBrayer, et al. The acute effects of nefazodone, trazodone and buspirone on sleep and sleep-related penile tumescence in normal subjects. Sleep: Journal of Sleep Research & Sleep Medicine. 1994;17(6):544-550.
Watanabe T, Chancellor MB, Rivas DA, et al. Epidemiology of current treatment for sexual dysfunction in spinal cord injured men in the USA model spinal cord injury centers. J Spinal Cord Med. 1996;19(3):186-189. [pmid: 8819027].
Webb DJ, Freestone S, Allen MJ, et al. Sildenafil citrate and blood-pressure-lowering drugs: results of drug interaction studies with an organic nitrate and a calcium antagonist. Am J Cardiol. 1999;83(5A):21C-28C. [pmid: 10073779].
Webb DJ, Muirhead GJ, Wulff M, et al. Sildenafil citrate potentiates the hypotensive effects of nitric oxide donor drugs in male patients with stable angina. J Am Coll Cardiol. 2000;36(1):25-31. [pmid: 10898408].
Wegner HEH, Knispel HH, Meier T, et al. Nitric oxide donor, linsidomine chlorhydrate (SIN-1), in the diagnosis and treatment of erectile dysfunction: Critical appraisal and review of the literature. International Urology & Nephrology. 1995;27(5):621-628. [pmid: 8775048].
Weinhardt LS, Carey MP. Prevalence of erectile disorder among men with diabetes mellitus: Comprehensive review, methodological critique, and suggestions for future research. J Sex Res. 1996;33(3):205-214.
Weinsaft JW, Hickey K, Bokhari S, et al. Effects of tadalafil on myocardial blood flow in patients with coronary artery disease. Coron Artery Dis. 2006;17(6):493-499. [pmid: 16905960].
Weiske WH. Invasive diagnosis and therapy - Are they still reasonable in the age of sildenafil?. Andrologia. 1999;31(SUPPL. 1):95-97. [pmid: 10643526].
Wespes E, Rammal A, Garbar C. Sildenafil non-responders: haemodynamic and morphometric studies. Eur Urol. 2005;48(1):136-139. [pmid: 15967263].
Wessells H, Fuciarelli K, Hansen J, et al. Synthetic melanotropic peptide initiates erections in men with psychogenic erectile dysfunction: double-blind, placebo controlled crossover study. Br J Urol. 1998;160(2):389-393.
Wessells H, Gralnek D, Dorr R, et al. Effect of an alpha-melanocyte stimulating hormone analog on penile erection and sexual desire in men with organic erectile dysfunction. Urology. 2000;56(4):641-646. [pmid: 11018622].
Wheatley D. Triple-blind, placebo-controlled trial of Ginkgo biloba in sexual dysfunction due to antidepressant drugs. Hum Psychopharmacol. 2004;19(8):545-548. [pmid: 15378664].
Wilke DR, Parker C, Andonowski A, et al. Testosterone and erectile function recovery after radiotherapy and long-term androgen deprivation with luteinizing hormone-releasing hormone agonists. BJU Int. 2006;97(5):963-968. [pmid: 16542340].
Williams G. Male erectile dysfunction. Prescribers' Journal. 2000;40(1):49-58.
Williams T, Honeywell M, Branch E et al. Tadalafil in the treatment of erectile dysfunction. P & T 2004;29(5):
Wilt TJ, Fink HA. Is antidepressant plus sildenafil a recipe for priapism?. Postgrad Med. 2004;116(6):11-12. [pmid: 15620123].
Witt Deborah K. Yohimbine for erectile dysfunction. J Fam Pract. 1998;46(4):282-283. [pmid: 9564368].
Wood P L. Slow, tedious but essential: The need for incremental R&D. Current Drug Discovery 2004;(pp 31–35):-35.
Wyllie MG. The hunt for pink Viagra. BJU Int. 2005;95(1):181-182. [pmid: 15638919].
Wyllie MG. Let's hope for more in 2004. BJU Int. 2004;93(1):175-176. [pmid: 14678392].
Wyllie MG. The Second International Consultation on Erectile Dysfunction: Highlights from the pharmaceutical industry. BJU Int. 2003;92(6):645-646. [pmid: 14511053].
Wyllie MG. The genesis of a phytopharmaceutical industry (Mark II). BJU Int. 2003;91(7):721-722. [pmid: 12699492].
Yajima T, Yajima Y, Koppiker N, et al. No clinically important effects on intraocular pressure after short-term administration of sildenafil citrate (Viagra). Am J Ophthalmol. 2000;129(5):675-676. [pmid: 10844068].
Yaman O, Akand M, Gursoy A, et al. The effect of diabetes mellitus treatment and good glycemic control on the erectile function in men with diabetes mellitus-induced erectile dysfunction: a pilot study. Br J Sex Med. 2006;3(2):344-348.
Yaman O, Tokatli Z, Akand M, et al. Characteristics of sildenafil erections in healthy young men. Asian J Androl. 2005;7(4):395-398. [pmid: 16281087].
Yamanaka M, Shirai M, Shiina H, et al. Vascular endothelial growth factor restores erectile function through inhibition of apoptosis in diabetic rat penile crura. Br J Urol. 2005;173(1):318-323.
Yan JY, Yang WZ. A comparative effects of Sildenafil and Yohimbine for the treatment of erectile dysfunction. Chinese Journal of Andrology. 2000;14(2):103-105.
Yarkony GM. Enhancement of sexual function and fertility in spinal cord-injured males. [Review] [40 refs]. Am J Phys Med Rehabil. 1990;69(2):81-87. [pmid: 2184843].
Yassin AA, Saad F. Treatment of sexual dysfunction of hypogonadal patients with long-acting testosterone undecanoate (Nebido). [Review] [25 refs]. World J Urol. 2006;24(6):639-644. [pmid: 17048032].
Yassin AA, Saad F. Dramatic improvement of penile venous leakage upon testosterone administration. A case report and review of literature. Andrologia. 2006;38(1):34-37. [pmid: 16420241].
Yasumoto R, Nishisaka N, Sakakura T, et al. Ethanol embolization for impotent patients with venous leakage: A new technique and initial results. Minimally Invasive Therapy & Allied Technologies: Mitat. 1996;5(6):564-566.
Yeager J, Beihn RM. Retention and migration of alprostadil cream applied topically to the glans meatus for erectile dysfunction. Int J Impot Res. 2005;17(1):91-95. [pmid: 15538395].
Youssef AF, Fort FL, Ronsen B, et al. Evaluation of apomorphine HCl effects on reproductive endpoints: Studies in male rats and dogs. J Toxicol Sci. 1999;51(2):273-279.
Zaslau S, Nicolis C, Galea G, et al. A simplified pharmacologic erection program for patients with spinal cord injury. J Spinal Cord Med. 1999;22(4):303-307. [pmid: 10751135].
Zasler ND. Therapeutic approaches to sexual impotence. Hospital Practice (Office Edition). 1988;23(7):197-200.
Zhao L. Clinical observation on the therapeutic effects of heavy moxibustion plus point-injection in treatment of impotence. J Tradit Chin Med. 2004;24(2):126-127. [pmid: 15270266].
Zhigang Long, Xiaowei Liu, Shengbo Lu. Therapy of impotence with traditional Chinese medicine. Journal of Sex Education & Therapy. 1994;20(2):140-143.
Ziegler D. Management of erectile dysfunction in diabetic patients. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):58-65.
Zini Dante, Carani Cesare, Baldini Augusto, et al. Sexual behavior of men with isolated hypogonadotropic hypogonadism or prepubertal anterior panhypopituitarism. Horm Behav. 1990;24(2):174-185. [pmid: 2365300].
Zlotta AR, Teillac P, Raynaud JP, et al. Evaluation of male sexual function in patients with Lower Urinary Tract Symptoms (LUTS) associated with Benign Prostatic Hyperplasia (BPH) treated with a phytotherapeutic agent (Permixon), Tamsulosin or Finasteride. Eur Urol. 2005;48(2):269-276. [pmid: 15939527].
Zusman RM. Cardiovascular data on sildenafil citrate: introduction.[erratum appears in Am J Cardiol 1999 Jul 15;84(2):244]. Am J Cardiol. 1999;83(5A):1C-2C. [pmid: 10073775].
Zusman RM, Morales A, Glasser DB, et al. Overall cardiovascular profile of sildenafil citrate. [Review] [33 refs]. Am J Cardiol. 1999;83(5A):35C-44C.
Zusman RM, Prisant LM, Brown MJ. Effect of sildenafil citrate on blood pressure and heart rate in men with erectile dysfunction taking concomitant antihypertensive medication. Sildenafil Study Group. J Hypertens. 2000;18(12):1865-1869. [pmid: 11132612].

## Observational injection study with < 6 months followup in duration

Bancroft J, Smith G, Munoz M, et al. Erectile response to visual erotic stimuli before and after intracavernosal papaverine, and its relationship to nocturnal penile tumescence and psychometric assessment. Br J Urol. 1991;68(6):629-638. [pmid: 1773296].
Beretta G, Marzotto M, Zanollo A, et al. Office treatment: intracavernous injections of prostaglandin E1 (PG E1) and improvement of spontaneous erections. Acta Eur Fertil. 1991;22(4):221-223. [pmid: 1844326].
Bird TD, Lipe HP, Crabtree LD. Impotence associated with the Charcot-Marie-Tooth syndrome. Eur Neurol. 1994;34(3):155-157. [pmid: 8033941].
Brown SL, Haas CA, Koehler M, et al. Hepatotoxicity related to intracavernous pharmacotherapy with papaverine. Urology. 1998;52(5):844-847. [pmid: 9801111].
Casella R, Deckart A, Bachmann A, et al. The patient's self-evaluation better predicts the degree of erectile dysfunction than the response to intracavernous alprostadil testing. Urol Int. 2004;72(3):216-220. [pmid: 15084765].
Chatterjee R, Kottaridis PD, McGarrigle HH, et al. Management of erectile dysfunction by combination therapy with testosterone and sildenafil in recipients of high-dose therapy for haematological malignancies. Bone Marrow Transplant. 2002;29(7):607-610. [pmid: 11979311].
Chun SS, Fenemore J, Heaton JP, et al. Enhancement of erectile responses to vasoactive drugs by a variable amplitude oscillation device. Int J Impot Res. 1996;8(4):221-225. [pmid: 8981171].
Dinsmore WW, Alderdice DK. Vasoactive intestinal polypeptide and phentolamine mesylate administered by autoinjector in the treatment of patients with erectile dysfunction resistant to other intracavernosal agents. Br J Urol. 1998;81(3):437-440. [pmid: 9523666].
Fein RL. Classification of sexual dysfunction for management of intracavernous medication-induced erections.[see comment]. Br J Urol. 1990;143(2):298-301.
Goonawardena SA, de Silva WA, Ketheeswaran T. Pharmacologically induced penile erections in the assessment and treatment of erectile impotence: a preliminary study of 100 patients. Ceylon Med J. 1997;42(2):72-74. [pmid: 9257465].
Greco E, Balbi PP, Virag R. Self intra-cavernous injections as a successful treatment in pure neurogenic impotence. Riv Neurol. 1991;61(1):35-38. [pmid: 1857921].
Kadioglu A, Erdogru T, Tellaloglu S. Combined intracavernous injection of papaverine and stimulation (CIS) test. J Androl. 1994;15(Suppl):50S-53S. [pmid: 7721678].
Katlowitz NM, Albano GJ, Morales P, et al. Potentiation of drug-induced erection with audiovisual sexual stimulation. Urology. 1993;41(5):431-434. [pmid: 8488610].
Katlowitz N, Albano GJ, Patsias G, et al. Effect of multidose intracorporeal injection and audiovisual sexual stimulation in vasculogenic impotence. Urology. 1993;42(6):695-697. [pmid: 8256402].
Kim JM, Joh YD, Huh JD, et al. Doppler sonography of the penile cavernosal artery: comparison of intraurethral instillation and intracorporeal injection of prostaglandin E1. J Clin Ultrasound. 2001;29(5):273-278. [pmid: 11486321].
Knispel HH. Penile venous surgery in impotence: results in highly selected cases. Urol Int. 1991;47(3):144-148. [pmid: 1771702].
Kromann-Andersen B. Intracavernosal pharmacotherapy with injection pen. Lancet. 1988;1(85756):54-59. [pmid: 2891913].
Mansi MK, Alkhudair WK, Huraib S. Treatment of erectile dysfunction after kidney transplantation with intracavernosal self-injection of prostaglandin E1. Br J Urol. 1998;159(6):1927-1930.
McMahon CG. A pilot study of the role of intracavernous injection of vasoactive intestinal peptide (VIP) and phentolamine mesylate in the treatment of erectile dysfunction. Int J Impot Res. 1996;8(4):233-236. [pmid: 8981173].
McMahon CG. Priapism associated with concurrent use of phosphodiesterase inhibitor drugs and intracavernous injection therapy. Int J Impot Res. 2003;15(5):383-384. [pmid: 14562142].
Metawea B, El-Nashar AR, Gad-Allah A, et al. Intracavernous papaverine/phentolamine-induced priapism can be accurately predicted with color Doppler ultrasonography. Urology. 2005;66(4):858-860. [pmid: 16230153].
Mirone V, Imbimbo C, Fabrizio F, et al. Ketanserin plus prostaglandin E1 (PGE-1) as intracavernosal therapy for patients with erectile dysfunction unresponsive to PGE-1 alone. Br J Urol. 1996;77(5):736-739. [pmid: 8689122].
Nagai A, Kusumi N, Tsuboi H, et al. Intracavernous injection of prostaglandin E1 is effective in patients with erectile dysfunction not responding to phosphodiseterase 5 inhibitors. Acta Med Okayama. 2005;59(6):279-280. [pmid: 16418771].
Nalesnik JG, Jones L, Kraus SR. Group B streptococcal septicemia following intracavernous injection therapy for erectile dysfunction in diabetes. Br J Urol. 2004;172(1):151-152.
Pagani E, Puech-Leao P, Glina S, et al. The value of a second injection on the pharmaco-induced erection test. Int J Impot Res. 1997;9(3):167-168. [pmid: 9315495].
Price DE, Cooksey G, Jehu D, et al. The management of impotence in diabetic men by vacuum tumescence therapy. Diabet Med. 1991;8(10):964-967. [pmid: 1838050].
Rodilla F, Fuentes MD, Chuan P, et al. Penile self-injection for impotence in patients after radical cystectomy. Journal of Clinical Pharmacy & Therapeutics. 1994;19(6):359-360. [pmid: 7876367].
Rodrigues M, Granegger S, O'Grady J, et al. Accumulation of platelets as a key mechanism of human erection. A scintigraphic study in patients with erectile dysfunction receiving intracavernous injection of PGE1, papaverine/phentolamine. Advances in Experimental Medicine & Biology. 1997;43:379-82.
Schouman M, Lacroix P, Amer M. Suppression of prostaglandin E1-induced pain by dilution of the drug with lidocaine before intracavernous injection. Br J Urol. 1992;148(4):1266.
Sparwasser C, Treiber U, Bahren W, et al. Postoperative erectile dysfunction; evaluation and treatment with intracavernous vasoactive injections. Progress in Clinical & Biological Research. 1991;370:349-354. [pmid: 1924468].
Stief CG, Holmquist F, Djamilian M, et al. Preliminary results with the nitric oxide donor linsidomine chlorhydrate in the treatment of human erectile dysfunction. Br J Urol. 1992;148(5):1437-1440.
Stief CG, Wetterauer U, Schaebsdau FH, et al. Calcitonin-gene-related peptide: a possible role in human penile erection and its therapeutic application in impotent patients. Br J Urol. 1991;146(4):1010-1014.
Vickers MA, De Nobrega AM, Dluhy RG. Diagnosis and treatment of psychogenic erectile dysfunction in a urological setting: Outcomes of 18 consecutive patients. Br J Urol. 1993;149(5 SUPPL.):1258-1261.
Weiss JN, Ravalli R, Badlani GH. Intracavernous pharmacotherapy in psychogenic impotence. Urology. 1991;37(5):441-443. [pmid: 1708925].

## Observational injection study > or = to 6 months in duration

al-Juburi AZ, O'Donnell PD. Follow up outcome of intracavernous papaverine. J Ark Med Soc. 1990;86(10):383-385. [pmid: 2138146].
Armstrong DK, Convery AG, Dinsmore WW. Reasons for patient drop-out from an intracavernous auto-injection programme for erectile dysfunction. Br J Urol. 1994;74(1):99-101. [pmid: 8044533].
Chang DW, Wood CG, Kroll SS, et al. Cavernous nerve reconstruction to preserve erectile function following non-nerve-sparing radical retropubic prostatectomy: a prospective study. Keisei Geka. 2003;111(3):1174-1181.
Chen J, Godschalk MF, Katz PG, et al. Incidence of penile pain after injection of a new formulation of prostaglandin E1.[see comment]. Br J Urol. 1995;154(1):77-79.
Chen J, Godschalk MF, Katz PG, et al. Combining intracavernous injection and external vacuum as treatment for erectile dysfunction.[see comment]. Br J Urol. 1995;153(5):1476-1477.
Cooper AJ. Evaluation of I-C papaverine in patients with psychogenic and organic impotence. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 1991;36(8):574-578. [pmid: 1742710].
Dhabuwala CB, Kerkar P, Bhutwala A, et al. Intracavernous papaverine in the management of psychogenic impotence. Arch Androl. 1990;24(2):185-191. [pmid: 2327828].
Fedele D, Coscelli C, Cucinotta D, et al. Management of erectile dysfunction in diabetic subjects: results from a survey of 400 diabetes centres in Italy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14(5):277-282.
Fein RL. Classification of sexual dysfunction for management of intracavernous medication-induced erections.[see comment]. Br J Urol. 1990;143(2):298-301.
Fugl-Meyer AR, Lodnert G, Branholm IB, et al. On life satisfaction in male erectile dysfunction. Int J Impot Res. 1997;9(3):141-148. [pmid: 9315491].
Godschalk M, Gheorghiu D, Chen J, et al. Long-term efficacy of a new formulation of prostaglandin E1 as treatment for erectile failure. Br J Urol. 1996;155(3):915-917.
Govier FE, McClure RD, Weissman RM, et al. Experience with triple-drug therapy in a pharmacological erection program.[see comment]. Br J Urol. 1993;150(6):1822-1824.
Incrocci L, Hop WC, Slob AK. Visual erotic and vibrotactile stimulation and intracavernous injection in screening men with erectile dysfunction: a 3 year experience with 406 cases. Int J Impot Res. 1996;8(4):227-232. [pmid: 8981172].
Irwin MB, Kata EJ. High attrition rate with intracavernous injection of prostaglandin E1 for impotency. Urology. 1994;43(1):84-87. [pmid: 8284888].
Jiann BP, Yu CC, Su CC. Impact of introduction of sildenafil on other treatment modalities for erectile dysfunction: A study of nationwide and local hospital sales. Int J Impot Res. 2004;16(6):527-530. [pmid: 15229626].
Kattan SA. The acceptance of satisfaction of Saudi males to vasoactive autoinjection intracavernous therapy, external negative pressure device and penile prosthesis in the treatment of erectile dysfunction. Ann Saudi Med. 2002;22(34):149-152. [pmid: 17159384].
Knispel HH, Huland H. Influence of cause on choice of therapy in 174 patients with erectile dysfunction. Br J Urol. 1992;147(5):1274-1276.
Lim PH, Ng FC. Erectile dysfunction in Singapore men: presentation, diagnosis, treatment and results. Ann Acad Med Singapore. 1992;21(2):248-253. [pmid: 1519896].
Lottman PE, Hendriks JC, Vruggink PA, et al. The impact of marital satisfaction and psychological counselling on the outcome of ICI-treatment in men with ED. Int J Impot Res. 1998;10(2):83-87. [pmid: 9647943].
Lundberg L, Olsson JO, Kihl B. Long-term experience of self-injection therapy with prostaglandin E1 for erectile dysfunction. Scand J Urol Nephrol. 1996;30(5):395-397. [pmid: 8936629].
Maniam P, Seftel AD, Corty EW, et al. Nocturnal penile tumescence activity unchanged after long-term intracavernous injection therapy. Br J Urol. 2001;165(3):830-832.
Mark SD, Keane TE, Vandemark RM, et al. Impotence following pelvic fracture urethral injury: incidence, aetiology and management. Br J Urol. 1995;75(1):62-64. [pmid: 7850299].
Montorsi F, Guazzoni G, Bergamaschi F, et al. Effectiveness and safety of multidrug intracavernous therapy for vasculogenic impotence. Urology. 1993;42(5):554-558. [pmid: 7694416].
Montorsi F, Guazzoni G, Bergamaschi F, et al. Four-drug intracavernous therapy for impotence due to corporeal veno-occlusive dysfunction. Br J Urol. 1993;149(5 Pt 2):1291-1295.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Intracavernous vasoactive pharmacotherapy: the impact of a new self-injection device.[see comment]. Br J Urol. 1993;150(6):1829-1832.
Mulhall JP, Jahoda AE, Cairney M, et al. The causes of patient dropout from penile self-injection therapy for impotence. Br J Urol. 1999;162(4):1291-1294.
Mulhall JP, Land S, Parker M, et al. The use of an erectogenic pharmacotheraphy regimen following radical prostatectomy improves recovery of spontaneous erectile function. Br J Sex Med. 2005;2(4):532-542.
Perimenis P, Athanasopoulos A, Geramoutsos I, et al. The incidence of pharmacologically induced priapism in the diagnostic and therapeutic management of 685 men with erectile dysfunction. Urol Int. 2001;66(1):27-29. [pmid: 11150947].
Rowland DL, Boedhoe HSM, Dohle G, et al. Intracavernosal self-injection therapy in men with erectile dysfunction: Satisfaction and attrition in 119 patients. Int J Impot Res. 1999;11(3):145-151. [pmid: 10404283].
Sparwasser C, Treiber U, Bahren W, et al. Postoperative erectile dysfunction; evaluation and treatment with intracavernous vasoactive injections. Progress in Clinical & Biological Research. 1991;370:349-354. [pmid: 1924468].
Speckens AE, Kattemolle MR, Hengeveld MW, et al. A prospective long-term follow-up study of patients evaluated for erectile dysfunction: outcome and associated factors. Int J Impot Res. 1995;7(2):101-110. [pmid: 7496438].
Tariq SH, Haleem U, Omran ML, et al. Erectile dysfunction: Etiology and treatment in young and old patients. Clin Geriatr Med. 2003;19(3):539-551. [pmid: 14567006].
Turner LA, Althof SE. The clinical effectiveness of self-injection and external vacuum devices in the treatment of erectile dysfunction: a six-month comparison. Psychiatr Med. 1992;10(2):283-293. [pmid: 1377397].
Virag R. Intracavernous injection of papaverine for erectile failure. 1982. Br J Urol. 2002;167(2 Pt 2):1196.
Weidner W, Schroeder-Printzen I, Fischer C, et al. Experience in the treatment of erectile dysfunction using the intracavernosal self-injection of papaverine: Results of a prospective study after a median follow-up of 42 months involving 135 patients and 10766 injections. World J Urol. 1992;10(3):179-182.
Weiss JN, Badlani GH, Ravalli R, et al. Reasons for high drop-out rate with self-injection therapy for impotence. Int J Impot Res. 1994;6(3):171-174. [pmid: 7735362].

## Not relevant by study design

Allan CA, McLachlan RI. Age-related changes in testosterone and the role of replacement therapy in older men. Clin Endocrinol (Oxf). 2004;60(6):653-670. [pmid: 15163327].
Anderson DC, Seifert CF. Topical nitrate treatment of impotence. [Review] [17 refs]. Ann Pharmacother. 1993;27(10):1203-1205. [pmid: 8251690].
Anonymous. Sildenafil for erectile dysfunction. Drug Ther.Bull 1998;36(11):81–84.
Anonymous. Vardenafil (levitra) for erectile dysfunction. Medical Letter on Drugs & Therapeutics 2003;45(1166):77–78.
Anonymous. Vasoactive intestinal peptide/phentolamine. Invicorp, vasopotin. Drugs in R &D 1999;2(6):436–438.
Berner M M, Kriston L, Harms A. Efficacy of PDE-5-inhibitors for erectile dysfunction. A comparative meta-analysis of fixed-dose regimen randomized controlled trials administering the International Index of Erectile Function in broad-spectrum populations. Int J Impot Res 2005;
Blanker MH, Thomas S, Bohnen AM. Systematic review of Viagra RCTs. Br J Gen Pract. 2002;52(477):329. [pmid: 11942454].
Bolona ER, Uraga MV, Haddad RM, et al. Testosterone use in men with sexual dysfunction: a systematic review and meta-analysis of randomized placebo-controlled trials. Mayo Clin Proc. 2007;82(1):20-28. [pmid: 17285782].
Burls A, Gold L, Clark W. Systematic review of randomised controlled trials of sildenafil (Viagra) in the treatment of male erectile dysfunction. Br J Gen Pract. 2001;51(473):1004-1012. [pmid: 11766850].
Calof OM, Singh AB, Lee ML, et al. Adverse events associated with testosterone replacement in middle-aged and older men: A meta-analysis of randomized, placebo-controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60(11):1451-1457.
Carey MP, Johnson BT. Effectiveness of yohimbine in the treatment of erectile disorder: four meta-analytic integrations. Arch Sex Behav. 1996;25(4):341-360. [pmid: 8836468].
Carson CC, Burnett AL, Levine LA, et al. The efficacy of sildenafil citrate (Viagra) in clinical populations: an update. Urology. 2002;60(2 Suppl 2):12-27. [pmid: 12414330].
Chen CT, Valicenti RK, Lu J, et al. Does hormonal therapy influence sexual function in men receiving 3D conformal radiation therapy for prostate cancer?. Int J Radiat Oncol Biol Phys. 2001;50(3):591-595. [pmid: 11395224].
Chiang HS, Kao YH, Sheu MT. Papaverine and prostaglandin E1 gel applications for impotence. Ann Acad Med Singapore. 1995;24(5):767-769. [pmid: 8579329].
Crowe SM, Streetman DS. Vardenafil treatment for erectile dysfunction. [Review] [43 refs]. Ann Pharmacother. 2004;38(1):77-85. [pmid: 14742800].
Derry F, Hultling C, Seftel AD, et al. Efficacy and safety of sildenafil citrate (Viagra) in men with erectile dysfunction and spinal cord injury: a review. Urology. 2002;60(2 Suppl 2):49-57. [pmid: 12414333].
Ernst E, Pittler MH. Yohimbine for erectile dysfunction: a systematic review and meta-analysis of randomized clinical trials. J Urol. 1998;159(2):433-436. [pmid: 9649257].
Escobar-Jimenez F. [Efficacy and safety of sildenafil in men with type 2 diabetes mellitus and erectile dysfunction]. Med Clin (Barc). 2002;119(4):121-124. [pmid: 12106522].
Fink HA, Mac Donald R, Rutks IR, et al. Sildenafil for male erectile dysfunction: a systematic review and meta-analysis. Arch Intern Med. 2002;162(12):1349-1360. [pmid: 12076233].
Fink HA, MacDonald R, Rutks IR, et al. Trazodone for erectile dysfunction: a systematic review and meta-analysis. BJU Int. 2003;92(4):441-446. [pmid: 12930437].
Hellstrom WJ. Vardenafil: a new approach to the treatment of erectile dysfunction. [Review] [37 refs]. Curr Urol Rep. 2003;4(6):479-487. [pmid: 14622502].
Holmes S. Tadalafil: a new treatment for erectile dysfunction. BJU Int. 2003;91(6):466-468. [pmid: 12656894].
Isidori AM, Giannetta E, Gianfrilli D, et al. Effects of testosterone on sexual function in men: results of a meta-analysis. Clin Endocrinol (Oxf). 2005;63(4):381-394. [pmid: 16181230].
Jain P, Rademaker AW, McVary KT. Testosterone supplementation for erectile dysfunction: results of a meta-analysis. Br J Urol. 2000;164(2):371-375.
Keating GM, Scott LJ. Vardenafil: a review of its use in erectile dysfunction. Drugs. 2003;63(23):2673-2703. [pmid: 14636086].
Keating GM, Scott LJ. Spotlight on vardenafil in erectile dysfunction. Drugs Aging. 2004;21(2):135-140. [pmid: 14960129].
Kloner RA. Cardiovascular effects of the 3 phosphodiesterase-5 inhibitors approved for the treatment of erectile dysfunction. [Review] [57 refs]. Circulation. 2004;110(19):3149-3155. [pmid: 15533876].
Langtry HD, Markham A. Sildenafil: a review of its use in erectile dysfunction. Drugs. 1999;57(6):967-989. [pmid: 10400408].
Lewis RW. Intraurethral and topical agents. Med Actual. 2000;36(23):113-119.
Licht M R, Schover L R. Sildenafil (Viagra) for treating male erectile dysfunction. Cleve Clin J Med 1998;65(6):
Markou S, Perimenis P, Gyftopoulos K, et al. Vardenafil (Levitra) for erectile dysfunction: a systematic review and meta-analysis of clinical trial reports. Int J Impot Res. 2004;16(6):470-478. [pmid: 15229625].
McMahon CG. Topiglan: MacroChem. Curr Opin Investig Drugs. 2002;3(4):602-606.
Mikhail N. Does Testosterone Have a Role in Erectile Function?. Am J Med. 2006;119:373-382. [pmid: 16651047].
Montorsi F, McCullough A. Efficacy of sildenafil citrate in men with erectile dysfunction following radical prostatectomy: A systematic review of clinical data. Br J Sex Med. 2005;2(5):658-667.
Moore R A, Derry S, McQuay H J. Indirect comparison of interventions using published randomised trials: systematic review of PDE-5 inhibitors for erectile dysfunction. [Review][77 refs]. BMC Urol 2005;518
Moore R A, Edwards J E, McQuay H J. Sildenafil (Viagra) for male erectile dysfunction: a meta-analysis of clinical trial reports. BMC Urol. 2002;26
Morales A, Gingell C, Collins M, et al. Clinical safety of oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):69-73. [pmid: 9647940].
Padma-Nathan H, Eardley I, Kloner RA, et al. A 4-year update on the safety of sildenafil citrate (Viagra). [Review] [88 refs]. Urology. 2002;60(2:Suppl 2):Suppl-90.
Rashid A. The efficacy and safety of PDE5 inhibitors. [Review] [30 refs]. Clin Cornerstone. 2005;7(1):47-56. [pmid: 16156423].
Rudkin L, Taylor M J, Hawton K. Strategies for managing sexual dysfunction induced by antidepressant medication. [Review][61 refs]. Cochrane Database Syst Rev 2004;(4):CD003382
Setter SM, Iltz JL, Fincham JE, et al. Phosphodiesterase 5 inhibitors for erectile dysfunction. [Review] [75 refs]. Ann Pharmacother. 2005;39(78):1286-1295. [pmid: 15941818].
Sommer F, Engelmann U. Vardenafil: Bayer Yakuhin. Curr Opin Investig Drugs. 2002;3(4):607-613.
Sternbach Harvey. Age-associated testosterone decline in men: Clinical issues for psychiatry. Am J Psychiatry. 1998;155(10):1310-1318. [pmid: 9766760].
Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005;88(3):241-254. [pmid: 16162361].
Tomsak R. PDE5 inhibitors and permanent visual loss. Int J Impot Res. 2005;17(6):547-549. [pmid: 16193072].
Tran D, Howes LG. Cardiovascular safety of sildenafil. Drug Saf. 2003;26(7):453-460. [pmid: 12735784].
Urciuoli R, Cantisani T A, CarliniI M et al. Prostaglandin E1 for treatment of erectile dysfunction. Cochrane Database Syst Rev 2004;(2):CD001784

## Not an original study, or population of interest, intervention of interest, or outcome of interest

Abdallah HM. Comparison of Alprostadil (Caverject) and a combination of vasoactive drugs as local injections for the treatment of erectile dysfunction. Int Urol Nephrol. 1998;30(5):617-620. [pmid: 9934808].
Abrams J. Time course of the interaction between tadalafil and nitrates.[comment]. J Am Coll Cardiol. 2004;43(11):2150-2151. [pmid: 15172433].
Adaikan PG, Chong YS, Chew SSL, et al. Male sexual dysfunction. Curr Obstet Gynaecol. 2000;10(1):23-28.
Adams MA, Perdok RJ, Padley RJ, et al. Safety and tolerability of apomorphine SL in men with cardiovascular disorders. European Urology Supplements. 2002;1(3):28-32.
Agelink MW, Schmitz T, Rembrink K, et al. Cardiovascular effects of sildenafil citrate (Viagra): a naturalistic cross-over study. Eur J Med Res. 2001;6(11):459-464. [pmid: 11726304].
Ahuja SK, Krane NK, Hellstrom WJ. Penile prostheses in the management of impotence in patients with end-stage renal disease. J La State Med Soc. 1998;150(1):32-34. [pmid: 9448384].
Aizenberg Dov, Gur Shay, Zemishlany Zvi, et al. Mianserin, a 5-HT-sub(2a/2c) and alpha -sub-2 antagonist, in the treatment of sexual dysfunction induced by serotonin reuptake inhibitors. Clin Neuropharmacol. 1997;20(3):210-214. [pmid: 9197943].
Aizenberg Dov, Weizman Abraham, Barak Yoram, et al. Sildenafil for selective serotonin reuptake inhibitor-induced erectile dysfunction in elderly male depressed patients. [References]. J Sex Marital Ther. 2003;29(4):297-303. [pmid: 14504018].
al-Juburi AZ, O'Donnell PD. Follow up outcome of intracavernous papaverine. J Ark Med Soc. 1990;86(10):383-385. [pmid: 2138146].
Alivizatos G, Skolarikos A, Laguna P. Recent data upon impotence, incontinence and quality of life issues concerning radical prostatectomy. [Review] [74 refs]. Arch Esp Urol. 2003;56(3):321-330. [pmid: 12768997].
Allan CA, McLachlan RI. Age-related changes in testosterone and the role of replacement therapy in older men. Clin Endocrinol (Oxf). 2004;60(6):653-670. [pmid: 15163327].
Althof SE, Cappelleri JC, Shpilsky A, et al. Treatment responsiveness of the Self-Esteem And Relationship questionnaire in erectile dysfunction. Urology. 2003;61(5):888-892. [pmid: 12735997].
Althof SE, O'Leary MP, Cappelleri JC, et al. Self-esteem, confidence, and relationships in men treated with sildenafil citrate for erectile dysfunction: results of two double-blind, placebo-controlled trials. J Gen Intern Med. 2006;21(10):1069-1074. [pmid: 16836626].
Altwein JE, Keuler FU. Oral treatment of erectile dysfunction with apomorphine SL. [Review] [34 refs]. Urol Int. 2001;67(4):257-263. [pmid: 11741126].
Anderson DC, Seifert CF. Topical nitrate treatment of impotence. [Review] [17 refs]. Ann Pharmacother. 1993;27(10):1203-1205. [pmid: 8251690].
Anderson RA, Bancroft J, Wu FC. The effects of exogenous testosterone on sexuality and mood of normal men. Journal of Clinical Endocrinology & Metabolism. 1992;75(6):1503-1507. [pmid: 1464655].
Andersson KE. Pharmacology of penile erection. Pharmacol Rev. 2001;53(3):417-450. [pmid: 11546836].
Anonymous. Sildenafil and erectile dysfunction: new preparation. Helpful. Prescrire. Int 1998;7(38):163–165.
Anonymous. Sublingual apomorphine: new preparation. In erectile disorders: a narrow therapeutic margin. Prescrire. Int 2002;11(59):76–79.
Anonymous. Vardenafil (levitra) for erectile dysfunction. Medical Letter on Drugs & Therapeutics 2003;45(1166):77–78.
Anonymous. Viagra: a blueprint for safety and reliability. Johns Hopkins Medical Letter, Health After 50 2002;14(10):4–5.
Anonymous. Vasoactive intestinal peptide/phentolamine. Invicorp, vasopotin. Drugs in R & D 1999;2(6):436–438.
Anonymous. Treatment for impotence gains FDA approval. Am J Health Syst Pharm 1995;52(19):2078–2079.
Anonymous. L-arginine. Altern Med Rev 2005;10(2):139–147.
Anonymous. Use of sildenafil for ED classes II and III. S Afr Med J 2005;95(1):38
Anonymous. Patient preference of ED drugs studied. British Journal of Diabetes &Vascular Disease 2003;3(6):444
Anonymous. New drug for erectile dysfunction. Can Pharm J 2002;268(7200):756
Anonymous. Vardenafil improves erectile function in men with diabetes. Can Pharm J 2001;267(7155):
Anonymous. Alprostadil for erectile impotence. Drug & Therapeutics Bulletin 1995;33(8):61–62.
Anonymous. What to do if Viagra won't do. Harvard Mens Health Watch 2005;9(10):4–8.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: intracavernous injection of prostaglandin E1. JAMA 1991;265(24):3321–3323.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: papaverine and phentolamine. JAMA 1990;264(6):752–754.
Aranda P, Ruilope LM, Calvo C, et al. Erectile dysfunction in essential arterial hypertension and effects of sildenafil: results of a Spanish national study. Am J Hypertens. 2004;17(2):139-145. [pmid: 14751656].
Ardicoglu A, Kocakoc E, Tuygun UO, et al. Effectiveness of vardenafil versus papaverine in penile Doppler ultrasonography. Urol Int. 2005;75(1):75-79. [pmid: 16037713].
Ardicoglu A, Kocakoc E, Yuzgec V, et al. Hemodynamic effects of sildenafil citrate (Viagra) on segmental branches of bilateral renal arteries. International Urology & Nephrology. 2005;37(4):785-789. [pmid: 16362600].
Armstrong DK, Convery AG, Dinsmore WW. Reasons for patient drop-out from an intracavernous auto-injection programme for erectile dysfunction. Br J Urol. 1994;74(1):99-101. [pmid: 8044533].
Armstrong DK, Convery A, Dinsmore WW. Prostaglandin E1 in the medical management of erectile dysfunction in a genito-urinary medicine clinic. Ulster Med J. 1994;63(1):18-22. [pmid: 8658990].
Arver S, Dobs AS, Meikle AW, et al. Improvement of sexual function in testosterone deficient men treated for 1 year with a permeation enhanced testosterone transdermal system. Br J Urol. 1996;155(5):1604-1608.
Ashok S, Sigman M. Bioavailable testosterone should be used for the determination of androgen levels in infertile men. Br J Urol. 2007;177(4):1443-1446.
Ashton Adam, Keller. Yohimbine in the treatment of male erectile dysfunction. Am J Psychiatry. 1994;151(9):1397. [pmid: 8067505].
Assalian Pierre. Sildenafil for St. John wort-induced sexual dysfunction. [References]. J Sex Marital Ther. 2000;26(4):357-358. [pmid: 11056902].
Atmaca M, Kuloglu M, Tezcan E. Sildenafil use in patients with olanzapine-induced erectile dysfunction. Int J Impot Res. 2002;14(6):547-549. [pmid: 12494295].
Aukst-Margetic B, Margetic B. An open-label series using loratadine for the treatment of sexual dysfunction associated with selective serotonin reuptake inhibitors. Prog Neuropsychopharmacol Biol Psychiatry. 2005;29(5):754-756. [pmid: 15913872].
Aversa A, Bonifacio V, Moretti C, et al. Re-dosing of prostaglandin-E1 versus prostaglandin-E1 plus phentolamine in male erectile dysfunction: a dynamic color power Doppler study. Int J Impot Res. 2000;12(1):33-40. [pmid: 10982310].
Aviv A, Shelef A, Weizman A. An open-label trial of sildenafil addition in risperidone-treated male schizophrenia patients with erectile dysfunction. Hillside J Clin Psychiatry. 2004;65(1):97-103.
Ayub W, Fletcher S. End-stage renal disease and erectile dysfunction. Is there any hope?. Nephrology Dialysis Transplantation. 2000;15(10):1525-1528.
Bacar MM, Batislam E, Altinok D, et al. Sildenafil citrate for penile hemodynamic determination: an alternative to intracavernosal agents in Doppler ultrasound evaluation of erectile dysfunction. Urology. 2001;57(4):623-626. [pmid: 11306361].
Bach Amy K, Barlow David H, Wincze John PE. The enhancing effects of manualized treatment for erectile dysfunction among men using sildenafil: A preliminary investigation. [References]. Behav Ther. 2004;35(1):55-73.
Bai WJ, Zhu JC, Jiang H, et al. [A comparative study of different vasoactive drugs in the treatment of impotence]. Chinese Journal of Urology. 1992;13(6):453-455.
Bain J. Andropause. Testosterone replacement therapy for aging men. [Review] [55 refs]. Can Fam Physician. 2001;47:91-97. [pmid: 11212438].
Balon Richard. Sildenafil and sexual dysfunction associated with antidepressants. [References]. J Sex Marital Ther. 1999;25(4):259-264. [pmid: 10546162].
Balon Richard. Fluvoxamine-induced erectile dysfunction responding to sildenafil. J Sex Marital Ther. 1998;24(4):313-317. [pmid: 9805292].
Bancroft J, Gutierrez P. Erectile dysfunction in men with and without diabetes mellitus: a comparative study.[see comment]. Diabet Med. 1996;13(1):84-89. [pmid: 8741818].
Bancroft J, Smith G, Munoz M, et al. Erectile response to visual erotic stimuli before and after intracavernosal papaverine, and its relationship to nocturnal penile tumescence and psychometric assessment. Br J Urol. 1991;68(6):629-638. [pmid: 1773296].
Baniel J, Israilov S, Engelstein D, et al. Three-year outcome of a progressive treatment program for erectile dysfunction with intracavernous injections of vasoactive drugs. Urology. 2000;56(4):647-652. [pmid: 11018623].
Barrou B, Cuzin B, Malavaud B, et al. Early experience with sildenafil for the treatment of erectile dysfunction in renal transplant recipients. Nephrol.Dial.Transplant. 2003;18(2):411-417. [pmid: 12543900].
Beal K, Mears JG. Short report: Penile lymphoma following local injections for erectile dysfunction. Leuk Lymphoma. 2001;42(12):247-249. [pmid: 11699217].
Becher E. Topical alprostadil cream for the treatment of erectile dysfunction. [Review] [46 refs]. Expert Opin Pharmacother. 2004;5(3):623-632. [pmid: 15013930].
Behrend L, Vibe-Petersen J, Perrild H. Sildenafil in the treatment of erectile dysfunction in men with diabetes: demand, efficacy and patient satisfaction. Int J Impot Res. 2005;17(3):264-269. [pmid: 15674401].
Bell DSH, Cutter GR, Hayne VB, et al. Factors predicting efficacy of phentolamine-papaverine intracorporeal injection for treatment of erectile dysfunction in diabetic male. Urology. 1992;40(1):36-40. [pmid: 1621310].
Benatov R, Reznik I, Zemishlany Z. Sildenafil citrate (Viagra) treatment of sexual dysfunction in a schizophrenic patient. [References]. Eur Psychiatry. 1999;14(6):353-355. [pmid: 10572370].
Benchekroun A, Faik M, Benjelloun S, et al. A baseline-controlled, open-label, flexible dose-escalation study to assess the safety and efficacy of sildenafil citrate (Viagra) in patients with erectile dysfunction. Int J Impot Res. 2003;15(Suppl 1):19-24.
Benevides MD, Carson CC. Intraurethral application of alprostadil in patients with failed inflatable penile prosthesis. Br J Urol. 2000;163(3):785-787.
Beretta G, Marzotto M, Zanollo A, et al. Office treatment: intracavernous injections of prostaglandin E1 (PG E1) and improvement of spontaneous erections. Acta Eur Fertil. 1991;22(4):221-223. [pmid: 1844326].
Berner M M, Kriston L, Harms A. Efficacy of PDE-5-inhibitors for erectile dysfunction. A comparative meta-analysis of fixed-dose regimen randomized controlled trials administering the International Index of Erectile Function in broad-spectrum populations. Int J Impot Res 2005;
Billington CJ, Shafer RB, Morley JE. Effects of opioid blockade with nalmefene in older impotent men. Life Sci. 1990;47(9):799-805. [pmid: 2120527].
Bird TD, Lipe HP, Crabtree LD. Impotence associated with the Charcot-Marie-Tooth syndrome. Eur Neurol. 1994;34(3):155-157. [pmid: 8033941].
Bischoff E. Vardenafil preclinical trial data: Potency, pharmacodynamics, pharmacokinetics, and adverse events. Int J Impot Res. 2004;16(SUPPL. 1):S34-S37. [pmid: 15224134].
Black AM, Day AG, Morales A. The reliability of clinical and biochemical assessment in symptomatic late-onset hypogonadism: Can a case be made for a 3-month therapeutic trial?. BJU Int. 2004;94(7):1066-1070. [pmid: 15541129].
Blanker MH, Thomas S, Bohnen AM. Systematic review of Viagra RCTs. Br J Gen Pract. 2002;52(477):329. [pmid: 11942454].
Blonde L. Sildenafil citrate for erectile dysfunction in men with diabetes and cardiovascular risk factors: a retrospective analysis of pooled data from placebo-controlled trials. Curr Med Res Opin. 2006;22(11):2111-2120. [pmid: 17076971].
Bocchi EA, Guimaraes G, Mocelin A, et al. Sildenafil effects on exercise, neurohormonal activation, and erectile dysfunction in congestive heart failure: a double-blind, placebo-controlled, randomized study followed by a prospective treatment for erectile dysfunction. Circulation. 2002;106(9):1097-1103. [pmid: 12196335].
Bodansky HJE. Successful tadalafil treatment for erectile dysfunction associated with Charcot-Marie-Tooth syndrome. [References]. Sexual and Relationship Therapy. 2006;21(1):87-89.
Bolona ER, Uraga MV, Haddad RM, et al. Testosterone use in men with sexual dysfunction: a systematic review and meta-analysis of randomized placebo-controlled trials. Mayo Clin Proc. 2007;82(1):20-28. [pmid: 17285782].
Bouloux P. Testim 1% testosterone gel for the treatment of male hypogonadism. [Review] [33 refs]. Clin Ther. 2005;27(3):286-298. [pmid: 15878382].
Boyarsky BK, Haque W, Rouleau MR, et al. Sexual functioning in depressed outpatients taking mirtazapine. Depression & Anxiety. 1999;9(4):175-179. [pmid: 10431683].
Braatvedt GD. Outcome of managing impotence in clinical practice. N Z Med J. 1999;112(1092):272-274. [pmid: 10472891].
Brazil M. Viagra for broken hearts?. Nat Rev Genet. 2005;4(3):190.
Briganti A, Salonia A, Gallina A, et al. Drug insight: Oral phosphodiesterase type 5 inhibitors for erectile dysfunction. Nature Clinical Practice Urology. 2005;2(5):239-247.
Brignardello E, Manti R, Papotti M, et al. Ectopic secretion of LH by an endocrine pancreatic tumor. J Endocrinol Invest. 2004;27(4):361-365. [pmid: 15233557].
Brindis RG, Kloner RA. Sildenafil in patients with cardiovascular disease. [Review] [33 refs]. Am J Cardiol. 2003;92(9A):26M-36M. [pmid: 12842240].
Brisson TE, Broderick GA, Thiel DD, et al. Vardenafil rescue rates of sildenafil nonresponders: objective assessment of 327 patients with erectile dysfunction. Urology. 2006;68(2):397-401. [pmid: 16904460].
Brock GB, McMahon CG, Chen KK, et al. Efficacy and safety of tadalafil for the treatment of erectile dysfunction: results of integrated analyses. Br J Urol. 2002;168(4 Pt 1):1332-1336.
Brock G, Chan J, Carrier S, et al. The treatment of erectile dysfunction study: focus on treatment satisfaction of patients and partners. BJU Int. 2007;99(2):376-382. [pmid: 17155989].
Brown SL, Haas CA, Koehler M, et al. Hepatotoxicity related to intracavernous pharmacotherapy with papaverine. Urology. 1998;52(5):844-847. [pmid: 9801111].
Buddeberg C, Bucher T, Hornung R. [Erectile dysfunction in men in their second half of life]. Urologe 2005;Ausg. A. 44(9):1045–1046, 1048–51.
Burge MR, Lanzi RA, Skarda ST, et al. Idiopathic hypogonadotropic hypogonadism in a male runner is reversed by clomiphene citrate. Fertility & Sterility. 1997;67(4):783-785. [pmid: 9093212].
Burls A, Gold L, Clark W. Systematic review of randomised controlled trials of sildenafil (Viagra) in the treatment of male erectile dysfunction. Br J Gen Pract. 2001;51(473):1004-1012. [pmid: 11766850].
Burnett AL. Vasoactive pharmacotherapy to cure erectile dysfunction: fact or fiction?. [Review] [45 refs]. Urology. 2005;65(2):224-230. [pmid: 15708027].
Burns-Cox N, Gingell C. The andropause: fact or fiction?. [Review] [49 refs]. Postgrad Med J. 1997;73(863):553-556. [pmid: 9373594].
Buvat J. Hyperprolactinemia and sexual function in men: a short review. [Review] [26 refs]. Int J Impot Res. 2003;15(5):373-377. [pmid: 14562140].
Buvat J, Montorsi F. Safety and tolerability of apomorphine SL in patients with erectile dysfunction. BJU Int. 2001;88(3):30-35. [pmid: 11578277].
Buvat J, Lemaire A, Ratajczyk J. Acceptance, efficacy and preference of Sildenafil in patients on long term auto-intracavernosal therapy: a study with follow-up at one year. Int J Impot Res. 2002;14(6):483-486. [pmid: 12494282].
Calof OM, Singh AB, Lee ML, et al. Adverse events associated with testosterone replacement in middle-aged and older men: A meta-analysis of randomized, placebo-controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60(11):1451-1457.
Cappelleri JC, Althof SE, Siegel RL, et al. Association between the Erectile Dysfunction Inventory of Treatment Satisfaction and the Self-Esteem and Relationship Questionnaire following treatment with sildenafil citrate for men with erectile dysfunction. Value Health. 2005;8(Suppl 1):54-60.
Cappelleri JC, Bell SS, Althof SE, et al. Comparison between sildenafil-treated subjects with erectile dysfunction and control subjects on the Self-Esteem And Relationship questionnaire. Br J Sex Med. 2006;3(2):274-282.
Carani C, Granata AR, Bancroft J, et al. The effects of testosterone replacement on nocturnal penile tumescence and rigidity and erectile response to visual erotic stimuli in hypogonadal men. Psychoneuroendocrinology. 1995;20(7):743-753. [pmid: 8848520].
Carani C, Zini D, Baldini A, et al. Effects of androgen treatment in impotent men with normal and low levels of free testosterone. Arch Sex Behav. 1990;19(3):223-234. [pmid: 2193636].
Caretta N, Palego P, Ferlin A, et al. Resumption of spontaneous erections in selected patients affected by erectile dysfunction and various degrees of carotid wall alteration: Role of tadalafil. Eur Urol. 2005;48(2):326-332. [pmid: 16005378].
Carey F, Quah SP, Dinsmore W. Postal survey to determine how many patients continued to seek treatment with sildenafil following sildenafil trials. Int J STD AIDS. 2003;14(7):501-502. [pmid: 12869236].
Carey MP, Johnson BT. Effectiveness of yohimbine in the treatment of erectile disorder: four meta-analytic integrations. Arch Sex Behav. 1996;25(4):341-360. [pmid: 8836468].
Carosa E, Martini P, Brandetti F, et al. Type V phosphodiesterase inhibitor treatments for erectile dysfunction increase testosterone levels. Clin Endocrinol (Oxf). 2004;61(3):382-386. [pmid: 15355456].
Carson CC, Burnett AL, Levine LA, et al. The efficacy of sildenafil citrate (Viagra) in clinical populations: an update. Urology. 2002;60(2 Suppl 2):12-27. [pmid: 12414330].
Carson CC, Rajfer J, Eardley I, et al. The efficacy and safety of tadalafil: an update. BJU Int. 2004;93(9):1276-1281. [pmid: 15180622].
Caruso S, Intelisano G, Farina M, et al. Efficacy and safety of daily intake of apomorphine SL in men affected by erectile dysfunction and mild hyperprolactinemia: a prospective, open-label, pilot study. Urology. 2003;62(5):922-927. [pmid: 14624921].
Casella R, Deckart A, Bachmann A, et al. The patient's self-evaluation better predicts the degree of erectile dysfunction than the response to intracavernous alprostadil testing. Urol Int. 2004;72(3):216-220. [pmid: 15084765].
Chaiban JT, Azar ST. Erectile dysfunction in diabetic patients. J Med Liban. 2004;52(4):217-219. [pmid: 16432985].
Chatterjee R, Kottaridis PD, McGarrigle HH, et al. Management of erectile dysfunction by combination therapy with testosterone and sildenafil in recipients of high-dose therapy for haematological malignancies. Bone Marrow Transplant. 2002;29(7):607-610. [pmid: 11979311].
Cheitlin MD, Hutter AM, Brindis RG, et al. Use of sildenafil (Viagra) in patients with cardiovascular disease. Circulation. 1999;99(1):168-177. [pmid: 9884398].
Chen JK, Hwang TI, Yang CR. Comparison of effects following the intracorporeal injection of papaverine and prostaglandin E1. Br J Urol. 1992;69(4):404-407. [pmid: 1581812].
Chen J, Godschalk MF, Katz PG, et al. Incidence of penile pain after injection of a new formulation of prostaglandin E1.[see comment]. Br J Urol. 1995;154(1):77-79.
Chen J, Godschalk MF, Katz PG, et al. Combining intracavernous injection and external vacuum as treatment for erectile dysfunction.[see comment]. Br J Urol. 1995;153(5):1476-1477.
Chen J, Godschalk M, Katz PG, et al. The lowest effective dose of prostaglandin E1 as treatment for erectile dysfunction. Br J Urol. 1995;153(1):80-81.
Chen J, Mabjeesh NJ, Greenstein A, et al. Clinical efficacy of sildenafil in patients on chronic dialysis. Br J Urol. 2001;165(3):819-821.
Chen J, Sofer M, Kaver I, et al. Concomitant use of sildenafil and a vacuum entrapment device for the treatment of erectile dysfunction. Br J Urol. 2004;171(1):292-295.
Chen KK, Jiann BP, Lin JSN, et al. Erratum: Efficacy and safety of on- demand oral tadalafil in the treatment of men eith erectile dysfunction in Taiwan: A randomized, double- blind, parallel, placebo- conrolled clinical study (Journal of Sexual Medicine vol. 1 (2)). Br J Sex Med. 2005;2(1):158.
Cheng E. Real-life safety and efficacy of vardenafil in the treatment of erectile dysfunction-results from 30,010 U.S. patients. Br J Sex Med. 2007;4(2):432-439.
Chew KK. Prevalence of hypogonadism in the aging male and male erectile dysfunction in Asia-Pacific countries. Asian J Androl. 2003;5(2):171-172.
Chew KK, Stuckey BGA. Use of transurethral alprostadil (MUSE) (prostaglandin E1) for glans tumescence in a patient with penile prosthesis. Int J Impot Res. 2000;12(3):195-196. [pmid: 11045915].
Chew KK, Stuckey BGA, Thompson PL. Erectile dysfunction, sildenafil and cardiovascular risk. Med J Aust. 2000;172(6):279-283. [pmid: 10860094].
Chia S. Management of premature ejaculation — a comparison of treatment outcome in patients with and without erectile dysfunction. Int J Androl. 2002;25(5):301-305. [pmid: 12270028].
Chia SJ, Ramesh K, Earnest A. Clinical application of prognostic factors for patients with organic causes of erectile dysfunction on 100 mg of sildenafil citrate. Int J Urol. 2004;11(12):1104-1109. [pmid: 15663683].
Chiang HS, Wen TC, Liang JF. Titration study of MUSE (Medicated Urethral System for Erection) in erectile dysfunction. J Formos Med Assoc. 2000;99(12):926-930. [pmid: 11155746].
Chiang HS, Kao YH, Sheu MT. Papaverine and prostaglandin E1 gel applications for impotence. Ann Acad Med Singapore. 1995;24(5):767-769. [pmid: 8579329].
Chiang PH, Tsai EM, Chiang CP. The role of trazodone in the treatment of erectile dysfunction. Kao-Hsiung i Hsueh Ko Hsueh Tsa Chih [Kaohsiung Journal of Medical Sciences]. 1994;10(6):287-294.
Chinegwundoh F, Anie K A. Treatments for priapism in boys and men with sickle cell disease. [Review][16 refs]. Cochrane Database Syst Rev 2004;(4):CD004198
Choi HK, Adimoelja A, Kim SC, et al. A dose-response study of alprostadil sterile powder (S.Po.) (Caverject) for the treatment of erectile dysfunction in Korean and Indonesian men. Int J Impot Res. 1997;9(1):47-51. [pmid: 9138059].
Christ B, Brockmeier D, Hauck EW, et al. Investigation on interaction between tacrolimus and sildenafil in kidney-transplanted patients with erectile dysfunction. International Journal of Clinical Pharmacology & Therapeutics. 2004;42(3):149-156. [pmid: 15049434].
Christ GJ, Melman A. The application of gene therapy to the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):111-112. [pmid: 9647947].
Chun SS, Fenemore J, Heaton JP, et al. Enhancement of erectile responses to vasoactive drugs by a variable amplitude oscillation device. Int J Impot Res. 1996;8(4):221-225. [pmid: 8981171].
Clark C. Erectile dysfunction and other problems. Can Pharm J. 2004;272(7299):608-610.
Claro JA, Ximenes SF, Nardozza A, et al. Effect of sildenafil in cavernous arteries of patients with erectile dysfunction. International Braz J Urol. 2003;29(4):320-326. [pmid: 15745555].
Cohen JS. Comparison of FDA reports of patient deaths associated with sildenafil and with injectable alprostadil. Ann Pharmacother. 2001;35(3):285-288. [pmid: 11261524].
Conti CR, Pepine CJ, Sweeney M. Efficacy and safety of sildenafil citrate in the treatment of erectile dysfunction in patients with ischemic heart disease. Am J Cardiol. 1999;83(5A):29C-34C.
Cooper AJ. Evaluation of I-C papaverine in patients with psychogenic and organic impotence. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 1991;36(8):574-578. [pmid: 1742710].
Copel L, Katz R, Blachar A, et al. Clinical and duplex US assessment of effects of sildenafil on cavernosal arteries of the penis: Comparison with intracavernosal injection of vasoactive agents - Initial experience. Radiology. 2005;237(3):986-991. [pmid: 16237136].
Corona G, Mannucci E, Fisher AD, et al. Effect of hyperprolactinemia in male patients consulting for sexual dysfunction. Br J Sex Med. 2007;4(5):1485-1493.
Corona G, Mannucci E, Schulman C, et al. Psychobiologic correlates of the metabolic syndrome and associated sexual dysfunction. Eur Urol. 2006;50(3):595-604. [pmid: 16564129].
Costabile RA, Spevak M, Fishman IJ, et al. Efficacy and safety of transurethral alprostadil in patients with erectile dysfunction following radical prostatectomy. Br J Urol. 1998;160(4):1325-1328.
Crowe SM, Streetman DS. Vardenafil treatment for erectile dysfunction. [Review] [43 refs]. Ann Pharmacother. 2004;38(1):77-85. [pmid: 14742800].
Curran M, Keating G. Tadalafil.[erratum appears in Drugs. 2003;63(23):2703]. [Review] [31 refs]. Drugs. 2003;63(20):2203-2212. [pmid: 14498756].
Dachille G, Pagliarulo V, Ludovico GM, et al. Sexual dysfunction in patients under dialytic treatment. Minerva Urol Nefrol. 2006;58(2):195-200. [pmid: 16767073].
Davis BE, Weigel JW, Whitford CS. Treatment of male impotence: a new option. Kans Med. 1990;91(12):325-326. [pmid: 1705298].
De Rose AF, Giglio M, Traverso P, et al. Combined oral therapy with sildenafil and doxazosin for the treatment of non-organic erectile dysfunction refractory to sildenafil monotherapy. Int J Impot Res. 2002;14(1):50-53. [pmid: 11896478].
De Meyer JM, Thibo P, Hatzichriston DG. The effect of re-dosing of vasodilators on the intracavernosal pressure and on the penile rigidity. Eur Urol. 1998;33(3):293-297. [pmid: 9555555].
De Siati M, Saugo M, Franzolin N. The start of pharmacological activity after sublingual administration of sildenafil citrate in 30 patients affected by erectile dysfunction. Arch Ital Urol Androl. 2003;75(1):18-20. [pmid: 12741340].
Decter RM, Furness PD, Nguyen TA, et al. Reproductive understanding, sexual functioning and testosterone levels in men with spina bifida. Br J Urol. 1997;157(4):1466-1468.
Derby CA, Araujo AB, Johannes CB, et al. Measurement of erectile dysfunction in population-based studies: the use of a single question self-assessment in the Massachusetts Male Aging Study. Int J Impot Res. 2000;12(4):197-204. [pmid: 11079360].
Derry F, Hultling C, Seftel AD, et al. Efficacy and safety of sildenafil citrate (Viagra) in men with erectile dysfunction and spinal cord injury: a review. Urology. 2002;60(2 Suppl 2):49-57. [pmid: 12414333].
Dhabuwala CB, Kerkar P, Bhutwala A, et al. Intracavernous papaverine in the management of psychogenic impotence. Arch Androl. 1990;24(2):185-191. [pmid: 2327828].
Dinsmore WW. Medical treatment of impotence with papaverine and phentolamine intracavernosal injection. Ulster Med J. 1990;59(2):174-176. [pmid: 2278115].
Dinsmore WW, Alderdice DK. Vasoactive intestinal polypeptide and phentolamine mesylate administered by autoinjector in the treatment of patients with erectile dysfunction resistant to other intracavernosal agents. Br J Urol. 1998;81(3):437-440. [pmid: 9523666].
Dizon MN, Vesely DL. Gonadotropin-secreting pituitary tumor associated with hypersecretion of testosterone and hypogonadism after hypophysectomy. Endocr Pract. 2002;8(3):225-231. [pmid: 12113637].
Doggrell SA. Comparison of clinical trials with sildenafil, vardenafil and tadalafil in erectile dysfunction. Expert Opin Pharmacother. 2005;6(1):75-84. [pmid: 15709885].
Donatucci CF, Lue TF. Erectile dysfunction in men under 40: etiology and treatment choice. Int J Impot Res. 1993;5(2):97-103. [pmid: 8348217].
Donatucci C, Eardley I, Buvat J, et al. Vardenafil improves erectile function in men with erectile dysfunction irrespective of disease severity and disease classification. Br J Sex Med. 2004;1(3):301-309.
Dundar SO, Dayanir Y, Topalolu A, et al. Effect of sildenafil on ocular hemodynamics in 3 months regular use. Int J Impot Res. 2006;18(3):282-286. [pmid: 16292333].
Dundar SO, Topalolu A, Dundar M, et al. Effects of sildenafil on blue-on-yellow and white-on-white Humphrey perimetry in 3 months regular use. Arb Paul Ehrlich Inst Georg Speyer Haus Ferdinand Blum Inst Frankf A M. 2006;20(7):810-813.
Dunn A. Sildenafil: A new therapy for erectile dysfunction. Conn Med. 1998;62(7):413-416. [pmid: 9707795].
Dusing R. Effect of the angiotensin II antagonist valsartan on sexual function in hypertensive men. Blood Pressure Supplement. 2003;2:29-34. [pmid: 14761074].
Eardley I. New oral therapies for the treatment of erectile dysfunction. Br J Urol. 1998;81(1):122-127. [pmid: 9467488].
El Malik EMA. Erectile dysfunction: An update of diagnosis and management. Qatar Medical Journal. 2000;9(2):9-17.
El-Sakka AI. Efficacy of sildenafil citrate in treatment of erectile dysfunction: effect of type 2 diabetes. Eur Urol. 2004;46(4):503-509. [pmid: 15363568].
El-Sakka AI. Efficacy of sildenafil citrate in treatment of erectile dysfunction: impact of associated premature ejaculation and low desire. Urology. 2006;68(3):642-647. [pmid: 16979718].
El-Sakka AI, Hassoba HM, Elbakry AM, et al. Prostatic specific antigen in patients with hypogonadism: Effect of testosterone replacement. Br J Sex Med. 2005;2(2):235-240.
Elhanbly S, Schoor R, Elmogy M, et al. What nonresponse to intracavernous injection really indicates: a determination by quantitative analysis. Br J Urol. 2002;167(1):192-196.
Engel JD, McVary KT. Transurethral alprostadil as therapy for patients who withdrew from or failed prior intracavernous injection therapy. Urology. 1998;51(5):687-692. [pmid: 9610580].
Engelhardt PF, Daha LK, Zils T, et al. Acupuncture in the treatment of psychogenic erectile dysfunction: first results of a prospective randomized placebo-controlled study. Int J Impot Res. 2003;15(5):343-346. [pmid: 14562135].
Engelhardt PF, Plas E, Hubner WA, et al. Comparison of intraurethral liposomal and intracavernosal prostaglandin-E1 in the management of erectile dysfunction. Br J Urol. 1998;81(3):441-444. [pmid: 9523667].
Engl T, Beecken WD, Wolfram M, et al. Uropharmacology: Current and future strategies in the treatment of erectile dysfunction and benign prostate hyperplasia. International Journal of Clinical Pharmacology & Therapeutics. 2004;42(10):527-533. [pmid: 15516021].
English JC, King DHC, Foley JP. Penile shaft hypopigmentation: Lichen sclerosus occurring after the initiation of alprostadil intracavernous injections for erectile dysfunction. J Am Acad Dermatol. 1998;39(5 I):801-803. [pmid: 9810901].
Erbagci A, Yagci F, Sarica K, et al. Evaluation and therapeutic regulation of erectile dysfunction with visual stimulation test. An objective approach by using sildenafil citrate test. Urol Int. 2002;69(1):21-26. [pmid: 12119434].
Erdogru T, Usta MF, Ceken K, et al. Is sildenafil citrate an alternative agent in the evaluation of penile vascular system with color Doppler ultrasound?. Urol Int. 2002;68(4):255-260. [pmid: 12053028].
Ernst E, Pittler MH. Yohimbine for erectile dysfunction: a systematic review and meta-analysis of randomized clinical trials. J Urol. 1998;159(2):433-436. [pmid: 9649257].
Escobar-Jimenez F. [Efficacy and safety of sildenafil in men with type 2 diabetes mellitus and erectile dysfunction]. Med Clin (Barc). 2002;119(4):121-124. [pmid: 12106522].
Espinoza R, Melchor JL, Gracida C. Sildenafil (Viagra) in kidney transplant recipients with erectile dysfunction. Transplant Proc. 2002;34(1):408-409. [pmid: 11959347].
Fagelman E, Fagelman A, Shabsigh R. Efficacy, safety, and use of sildenafil in urologic practice. Urology. 2001;57(6):1141-1144. [pmid: 11377328].
Fava M, Rankin MA, Alpert JE, et al. An open trial of oral sildenafilin antidepressant-induced sexual dysfunction. Psychotherapy & Psychosomatics. 1998;67(6):328-331. [pmid: 9817955].
Fazeli-Matin S, Montague DK, Angermeier KW, et al. Penile fracture after intracavernous injection therapy. Br J Urol. 1998;159(6):2094.
Fedele D, Coscelli C, Cucinotta D, et al. Management of erectile dysfunction in diabetic subjects: results from a survey of 400 diabetes centres in Italy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14(5):277-282.
Fein RL. Classification of sexual dysfunction for management of intracavernous medication-induced erections.[see comment]. Br J Urol. 1990;143(2):298-301.
Feldman R, Meuleman EJ, Steers W. Sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction: analysis of two flexible dose-escalation studies. Sildenafil Study Group. Int J Clin Pract. 1999;102(Suppl Jun.):100-102.
Fink HA, Mac Donald R, Rutks IR, et al. Sildenafil for male erectile dysfunction: a systematic review and meta-analysis. Arch Intern Med. 2002;162(12):1349-1360. [pmid: 12076233].
Fink HA, MacDonald R, Rutks IR, et al. Trazodone for erectile dysfunction: a systematic review and meta-analysis. BJU Int. 2003;92(4):441-446. [pmid: 12930437].
Fishbain David A. Impact of sildenafil on male erectile disorder due to psychological factors. Can J Psychiatry. 2000;45(1):85-86. [pmid: 10696497].
Flack JM. The effect of doxazosin on sexual function in patients with benign prostatic hyperplasia, hypertension, or both.[see comment]. [Review] [47 refs]. Int J Clin Pract. 2002;56(7):527-530. [pmid: 12296615].
Fonseca V, Seftel A, Denne J, et al. Impact of diabetes mellitus on the severity of erectile dysfunction and response to treatment: analysis of data from tadalafil clinical trials. Diabetologia. 2004;47(11):1914-1923. [pmid: 15599697].
Foresta C, Caretta N, Lana A, et al. Relationship Between Vascular Damage Degrees and Endothelial Progenitor Cells in Patients with Erectile Dysfunction: Effect of Vardenafil Administration and PDE5 Expression in the Bone Marrow. Eur Urol. 2007;51(5):1411-1419. [pmid: 17034932].
Foresta C, Ferlin A, De Toni L, et al. Circulating endothelial progenitor cells and endothelial function after chronic Tadalafil treatment in subjects with erectile dysfunction. Int J Impot Res. 2006;18(5):484-488. [pmid: 16541115].
Foulks CJ, Cushner HM. Sexual dysfunction in the male dialysis patient: pathogenesis, evaluation, and therapy. [Review] [105 refs]. Am J Kidney Dis. 1986;8(4):211-222. [pmid: 3532769].
Fox KM, Thadani U, Ma PT, et al. Sildenafil citrate does not reduce exercise tolerance in men with erectile dysfunction and chronic stable angina. Eur Heart J. 2003;24(24):2206-2212. [pmid: 14659772].
Freitas D, Athanazio R, Almeida D, et al. Sildenafil improves quality of life in men with heart failure and erectile dysfunction. Int J Impot Res. 2006;18(2):210-212. [pmid: 16121207].
Fugl-Meyer AR, Lodnert G, Branholm IB, et al. On life satisfaction in male erectile dysfunction. Int J Impot Res. 1997;9(3):141-148. [pmid: 9315491].
Fugl-Meyer KS, Stothard D, Belger M, et al. The effect of tadalafil on psychosocial outcomes in Swedish men with erectile distress: a multicentre, non-randomised, open-label clinical study. Int J Clin Pract. 2006;60(11):1386-1393. [pmid: 17073836].
Fujisawa M, Sawada K. Clinical efficacy and safety of sildenafil in elderly patients with erectile dysfunction. Arch Androl. 2004;50(4):255-260. [pmid: 15277003].
Fulgham PF, Cochran JS, Denman JL, et al. Disappointing initial results with transurethral alprostadil for erectile dysfunction in a urology practice setting. Br J Urol. 1998;160(6 Pt 1):2041-2046.
Gana TE, Quizanos LF, Castell R, et al. A dose-response study of alprostadil in patients with erectile dysfunction. Curr Ther Res Clin Exp. 1996;57(9):700-710.
Garcia-Bravo AM, Suarez-Hernandez D, Ruiz-Fernandez MA, et al. Determination of changes in blood pressure during administration of sildenafil (Viagra) in patients with spinal cord injury and erectile dysfunction. Proc Annu Clin Spinal Cord Inj Conf. 2006;44(5):301-308.
Ghanem H, Sherif T, bdEl-Gawad T, et al. Short term use of intracavernous vasoactive drugs in the treatment of persistent psychogenic erectile dysfunction. Int J Impot Res. 1998;10(4):211-214. [pmid: 9884916].
Gheorghiu S, Godschalk M, Gentili A, et al. Quality of life in patients using self-administered intracavernous injections of prostaglandin E1 for erectile dysfunction. Br J Urol. 1996;156(1):80-81.
Giammusso B, Morgia G, Spampinato A, et al. Improved pallesthetic sensitivity of pudendal nerve in impotent diabetic patients treated with acetyl-L-carnitine. Acta Urologica Italica. 1996;10(3):185-187.
Gil A, Martinez E, Oyaguez I, et al. Erectile dysfunction in a primary care setting: results of an observational, no-control-group, prospective study with sildenafil under routine conditions of use. Int J Impot Res. 2001;13(6):338-347. [pmid: 11918250].
Gilbert HW, Gingell JC. The results of an intracorporeal papaverine clinic. Sex Marital Ther. 1991;6(1):49-56.
Gilbert HW, Gillatt DA, Desai KM, et al. Intracorporeal papaverine injection in androgen deprived men. J R Soc Med. 1990;83(3):161. [pmid: 2182861].
Gilbert R N, Graham C W, Regan J B. Double-blind-cross-over trial of testosterone enanthate in impotent men with low or low-normal serum testosterone levels. Br J Urol 1992;147264
Gillies HC, Roblin D, Jackson G. Coronary and systemic hemodynamic effects of sildenafil citrate: From basic science to clinical studies in patients with cardiovascular disease. Int J Cardiol. 2002;86(23):131-141. [pmid: 12419549].
Gingell C, Buvat J, Jardin A et al. Sildenafil citrate (VIAGRA(TM)), an oral treatment for erectile function: 1-year, open-label, extension studies. Int J Clin Pract 1999;(pp 30–31):-31.
Ginsberg DL. Vardenafil treatment of sertraline-induced sexual dysfunction. Primary Psychiatry. 2004;11(11):23-24.
Ginsberg David L. Sildenafil-dihydrocodeine interaction results in prolonged erections. [References]. Primary Psychiatry. 2003;10(2):23.
Ginzburg R, Wong Y, Fader JS. Effect of bupropion on sexual dysfunction. Ann Pharmacother. 2005;39(12):2096-2099. [pmid: 16288071].
Giuliano F, Donatucci C, Montorsi F, et al. Vardenafil is effective and well-tolerated for treating erectile dysfunction in a broad population of men, irrespective of age. BJU Int. 2005;95(1):110-116. [pmid: 15638906].
Giuliano F, Montorsi F, Mirone V, et al. Switching from intracavernous prostaglandin E1 injections to oral sildenafil citrate in patients with erectile dysfunction: results of a multicenter European study. The Sildenafil Multicenter Study Group. Br J Urol. 2000;164(3:Pt 1):t-11.
Giuliano F, Pena BM, Mishra A, et al. Efficacy results and quality-of-life measures in men receiving sildenafil citrate for the treatment of erectile dysfunction. Qual Life Res. 2001;10(4):359-369. [pmid: 11763248].
Giuliano F, Rubio-Aurioles E, Kennelly M, et al. Efficacy and safety of vardenafil in men with erectile dysfunction caused by spinal cord injury. Neurology. 2006;66(2):210-216. [pmid: 16434656].
Glenn DRJ, McClure N, Lewis SEM. The hidden impact of diabetes on male sexual dysfunction and fertility. Hum Fertil. 2003;6(4):174-179.
Glina S, Sotomayor M, Gatchalian E, et al. Timing of dose relative to sexual intercourse attempt in previous sildenafil citrate users treated with tadalafil. Br J Sex Med. 2006;3(2):309-319.
Godschalk MF, Chen J, Katz PG, et al. Prostaglandin E1 as treatment for erectile failure in elderly men. J Am Geriatr Soc. 1994;42(12):1263-1265. [pmid: 7983289].
Godschalk M, Gheorghiu D, Chen J, et al. Long-term efficacy of a new formulation of prostaglandin E1 as treatment for erectile failure. Br J Urol. 1996;155(3):915-917.
Gogtay NJ, Bichile SK, Pinto CJ, et al. Erectile dysfunction and sildenafil citrate.[comment]. J Assoc Physicians India. 2001;49:871-872. [pmid: 11837751].
Goldenberg MM. Safety and efficacy of sildenafil citrate in the treatment of male erectile dysfunction. Clin Ther. 1998;20(6):1033-1048. [pmid: 9916601].
Goldstein I. Oral phentolamine: an alpha-1, alpha-2 adrenergic antagonist for the treatment of erectile dysfunction. [Review][9 refs]. Int J Impot Res 2000;12Suppl-80.
Goldstein I. A 36-week, open label, non-comparative study to assess the long-term safety of sildenafil citrate (VIAGRA) in patients with erectile dysfunction. Int J Clin Pract 1999;Supplement.102–109.
Goldstein I, Auerbach S, Padma-Nathan H, et al. Axial penile rigidity as primary efficacy outcome during multi-institutional in-office dose titration clinical trials with alprostadil alfadex in patients with erectile dysfunction. Alprostadil Alfadex Study Group. Int J Impot Res. 2000;12(4):205-211. [pmid: 11079361].
Goldstein I, Kim E, Steers WD, et al. Efficacy and safety of tadalafil in men with erectile dysfunction with a high prevalence of comorbid conditions: results from MOMENTUS: multiple observations in men with erectile dysfunction in National Tadalafil Study in the US. Br J Sex Med. 2007;4(1):166-175.
Gomery P, Bullock A, McGettigan J, et al. Tadalafil is efficacious in Black American and Hispanic men with erectile dysfunction: results from multiple observations in men with erectile dysfunction in national tadalafil study in the US (MOMENTUS). Int J Impot Res. 2007;19(1):76-83. [pmid: 16728966].
Goonawardena SA, de Silva WA, Ketheeswaran T. Pharmacologically induced penile erections in the assessment and treatment of erectile impotence: a preliminary study of 100 patients. Ceylon Med J. 1997;42(2):72-74. [pmid: 9257465].
Gore JL, Swerdloff RS, Rajfer J. Androgen deficiency in the etiology and treatment of erectile dysfunction. Urol Clin North Am. 2005;32(4):457-468. [pmid: 16291037].
Govier FE, McClure RD, Weissman RM, et al. Experience with triple-drug therapy in a pharmacological erection program.[see comment]. Br J Urol. 1993;150(6):1822-1824.
Greco EA, Pili M, Bruzziches R, et al. Testosterone:estradiol ratio changes associated with long-term tadalafil administration: a pilot study. Br J Sex Med. 2006;3(4):716-722.
Greco E, Polonio-Balbi P. Penile rigidity in erectile dysfunction treated with alprostadil. Lancet. 1997;350(9092):1682. [pmid: 9400524].
Greco E, Balbi PP, Virag R. Self intra-cavernous injections as a successful treatment in pure neurogenic impotence. Riv Neurol. 1991;61(1):35-38. [pmid: 1857921].
Green BG, Martin S. Clinical assessment of sildenafil in the treatment of neurogenic male sexual dysfunction: After the hype. NeuroRehabilitation. 2000;15(2):101-105. [pmid: 11455087].
Greenstein A, Mabjeesh NJ, Sofer M, et al. Does sildenafil combined with testosterone gel improve erectile dysfunction in hypogonadal men in whom testosterone supplement therapy alone failed?[see comment]. Br J Urol. 2005;173(2):530-532.
Gresser U, Gleiter CH. Erectile dysfunction: comparison of efficacy and side effects of the PDE-5 inhibitors sildenafil, vardenafil and tadalafil—review of the literature. [Review] [92 refs]. Eur J Med Res. 2002;7(10):435-446. [pmid: 12435622].
Gross AJ, Sauerwein DH, Kutzenberger J, et al. Penile prostheses in paraplegic men. Br J Urol. 1996;78(2):262-264. [pmid: 8813925].
Grossman EB, Swan SK, Muirhead GJ, et al. The pharmacokinetics and hemodynamics of sildenafil citrate in male hemodialysis patients. Kidney Int. 2004;66(1):367-374. [pmid: 15200445].
Grover JK, Vats V, Ajeeta. Sildenafil (Viagra(TM)). Medico-Legal Update. 1998;3(12):67-78.
Guay AT, Perez JB, Jacobson J, et al. Efficacy and safety of sildenafil citrate for treatment of erectile dysfunction in a population with associated organic risk factors.[erratum appears in J Androl 2002 Jan-Feb;23(1):113]. J Androl. 2001;22(5):793-797. [pmid: 11545291].
Guay AT, Perez JB, Velasquez E, et al. Clinical experience with intraurethral alprostadil (MUSE) in the treatment of men with erectile dysfunction. A retrospective study. Medicated urethral system for erection. Eur Urol. 2000;38(6):671-676. [pmid: 11111182].
Guay AT, Spark RF, Jacobson J, et al. Yohimbine treatment of organic erectile dysfunction in a dose-escalation trial. Int J Impot Res. 2002;14(1):25-31. [pmid: 11896474].
Gupta N, Sawlani K K, Tripathi A K. Appropriate use of sildenafil citrate in male erectile dysfunction.[see comment]. [Review] [52 refs]. J Assoc Physicians India. 2001;49:889-896. [pmid: 11837756].
Gupta Sanjay, Masand Prakash, Ashton Adam K, et al. Phenelzine-induced sexual dysfunction treated with sildenafil. J Sex Marital Ther. 1999;25(2):131-135. [pmid: 10327382].
Gutierrez P, Hernandez P, Mas M. Combining programmed intracavernous PGE1 injections and sildenafil on demand to salvage sildenafil nonresponders. Int J Impot Res. 2005;17(4):354-358. [pmid: 15703770].
Hammadeh MY, Madaan S, Hines J, et al. 5-year outcome of a prospective randomized trial to compare transurethral electrovaporization of the prostate and standard transurethral resection. Urology. 2003;61(6):1166-1171. [pmid: 12809891].
Harding LM, Adeniyi A, Everson R, et al. Comparison of a needle-free high-pressure injection system with needle-tipped injection of intracavernosal alprostadil for erectile dysfunction. Int J Impot Res. 2002;14(6):498-501. [pmid: 12494285].
Harrold LR, Gurwitz JH, Field TS, et al. The diffusion of a novel therapy into clinical practice: the case of sildenafil.[see comment]. Arch Intern Med. 2000;160(22):3401-3405. [pmid: 11112232].
Harwood PJ, Grotz M, Eardley I, et al. Erectile dysfunction after fracture of the pelvis. Journal of Bone & Joint Surgery - British Volume. 2005;87(3):281-290.
Hatzichristou D G. Sildenafil citrate: lessons learned from 3 years of clinical experience. [Review][60 refs]. Int J Impot Res 2002;14Suppl-52.
Hatzichristou D G. Current treatment and future perspectives for erectile dysfunction. [Review][85 refs]. Int J Impot Res 1998;10Suppl-13.
Hatzichristou DG, Apostolidis A, Tzortzis V, et al. Sildenafil versus intracavernous injection therapy: efficacy and preference in patients on intracavernous injection for more than 1 year. Br J Urol. 2000;164(4):1197-1200.
Hatzichristou D, Vardi Y, Papp G, et al. Effect of tadalafil on sexual timing behavior patterns in men with erectile dysfunction: integrated analysis of randomized, placebo controlled trials. Br J Urol. 2005;174(4 Pt 1):1356-1359.
Hatzimouratidis K, Hatzichristou D. Phosphodiesterase Type 5 Inhibitors: The Day After. Eur Urol. 2007;51(1):75-89. [pmid: 16949200].
Hatzimouratidis K, Hatzichristou DG. A comparative review of the options for treatment of erectile dysfunction: Which treatment for which patient?. Drugs. 2005;65(12):1621-1650. [pmid: 16060698].
Hauck EW, Altinkilic BM, Schroeder-Printzen I, et al. Prostaglandin E1 long-term self-injection programme for treatment of erectile dysfunction—a follow-up of at least 5 years. Andrologia. 1999;31(Suppl):Suppl-103.
He XQ, Hong BF, Wang XX, et al. Evaluation of efficacy and safety of oral sildenafil citrate therapy for men with erectile dysfunction. Pharmaceutical Journal of Chinese Peoples Liberation Army. 2002;18(4):205-208.
Heaton JP. Key issues from the clinical trials of apomorphine SL. World J Urol. 2001;19(1):25-31. [pmid: 11289567].
Heaton JPW, Wagner Porst, Eid Wyllie. Apomorphine: An update of clinical trial results. Int J Impot Res. 2000;12(SUPPL. 4):S67-S73. [pmid: 11035390].
Heaton JP, Lording D, Liu SN, et al. Intracavernosal alprostadil is effective for the treatment of erectile dysfunction in diabetic men. Int J Impot Res. 2001;13(6):317-321. [pmid: 11918246].
Heaton JP, Morales A, Adams MA, et al. Recovery of erectile function by the oral administration of apomorphine. Urology. 1995;45(2):200-206. [pmid: 7855966].
Hellstrom WJ. Vardenafil: a new approach to the treatment of erectile dysfunction. [Review] [37 refs]. Curr Urol Rep. 2003;4(6):479-487. [pmid: 14622502].
Hirsch IH, Schanne FJ, Carsello J, et al. Sequential penile ultrasound monitoring of patients treated with chronic intracavernous prostaglandin E1. Urology. 1995;45(6):1037-1041. [pmid: 7771005].
Hirsch IH, Smith RL, Chancellor MB, et al. Use of intracavernous injection of prostaglandin E1 for neuropathic erectile dysfunction. Paraplegia. 1994;32(10):661-664. [pmid: 7831071].
Hollander JB, Gonzalez J, Norman T. Patient satisfaction with pharmacologic erection program. Urology. 1992;39(5):439-441. [pmid: 1580034].
Holmes S. Tadalafil: a new treatment for erectile dysfunction. BJU Int. 2003;91(6):466-468. [pmid: 12656894].
Hong EK, Lepor H, McCullough AR. Time dependent patient satisfaction with sildenafil for erectile dysfunction (ED) after nerve-sparing radical retropubic prostatectomy (RRP). Int J Impot Res. 1999;11(SUPPL. 1):S15-S22. [pmid: 10554925].
Hong JH, Ahn TY. Oral testosterone replacement in Korean patients with PADAM. Aging Male. 2002;5(1):52-56. [pmid: 12040976].
Hookes J. Asian Federation of Medicinal Chemistry (AFMC) - Fifth International Medicinal Chemistry Symposium: 14–17 October 2003, Kyoto, Japan. IDrugs. 2003;6(11):1013-1015. [pmid: 15270004].
Huang ST, Hsieh ML. Different hemodynamic responses by color Doppler ultrasonography studies between sildenafil non-responders and responders. Asian J Androl. 2007;9(1):129-133. [pmid: 17187164].
Hubler J, Szanto A, Konyves K. Methylene blue as a means of treatment for priapism caused by intracavernous injection to combat erectile dysfunction. International Urology & Nephrology. 2003;35(4):519-521. [pmid: 15198160].
Hwang TI, Chen HE, Tsai TF, et al. Combined use of androgen and sildenafil for hypogonadal patients unresponsive to sildenafil alone. Int J Impot Res. 2006;18(4):400-404. [pmid: 16395321].
Incrocci L, Hop WC, Slob AK. Visual erotic and vibrotactile stimulation and intracavernous injection in screening men with erectile dysfunction: a 3 year experience with 406 cases. Int J Impot Res. 1996;8(4):227-232. [pmid: 8981172].
Irwin MB, Kata EJ. High attrition rate with intracavernous injection of prostaglandin E1 for impotency. Urology. 1994;43(1):84-87. [pmid: 8284888].
Isidori AM, Giannetta E, Gianfrilli D, et al. Effects of testosterone on sexual function in men: results of a meta-analysis. Clin Endocrinol (Oxf). 2005;63(4):381-394. [pmid: 16181230].
Ismail M, Abbott L, Hirsch IH. Experience with intracavernous PGE-1 in the treatment of erectile dysfunction: dose considerations and efficacy. Int J Impot Res. 1997;9(1):39-42. [pmid: 9138057].
Israilov S, Niv E, Livne PM, et al. Intracavernous injections for erectile dysfunction in patients with cardiovascular diseases and failure or contraindications for sildenafil citrate. Int J Impot Res. 2002;14(1):38-43. [pmid: 11896476].
Israilov S, Shmuely J, Niv E, et al. Evaluation of a progressive treatment program for erectile dysfunction in patients with diabetes mellitus. Int J Impot Res. 2005;17(5):431-436. [pmid: 15889124].
Jackson G. Sildenafil (Viagra): New data, new confidence in treating erectile dysfunction in the cardiovascular patient. Int J Clin Pract. 2002;56(2):75. [pmid: 11926708].
Jackson G, Keltai M, Csanady M, et al. Hemodynamic effects of sildenafil citrate and isosorbide mononitrate in men with coronary artery disease and erectile dysfunction. Br J Sex Med. 2005;2(3):407-414.
Jackson G, Kloner RA, Costigan TM, et al. Update on clinical trials of tadalafil demonstrates no increased risk of cardiovascular adverse events. Br J Sex Med. 2004;1(2):161-167.
Jackson G, Montorsi P, Cheitlin MD. Cardiovascular safety of sildenafil citrate (Viagra): an updated perspective. [Review] [52 refs]. Urology. 2006;68(3 Suppl):47-60. [pmid: 17011375].
Jacobsen FM. Fluoxetine-induced sexual dysfunction and an open trial of yohimbine.[see comment]. Hillside J Clin Psychiatry. 1992;53(4):119-122.
Jain P, Rademaker AW, McVary KT. Testosterone supplementation for erectile dysfunction: results of a meta-analysis. Br J Urol. 2000;164(2):371-375.
Jarow JP, Burnett AL, Geringer AM. Clinical efficacy of sildenafil citrate based on etiology and response to prior treatment.[see comment]. Br J Urol. 1999;162(3:Pt 1):t-5.
Jiann BP, Yu CC, Su CC, et al. Rechallenge prior sildenafil nonresponders. Int J Impot Res. 2004;16(1):64-68. [pmid: 14963473].
Jiann BP, Yu CC, Tsai JY, et al. What to learn about sildenafil in the treatment of erectile dysfunction from 3-year clinical experience. Int J Impot Res. 2003;15(6):412-417. [pmid: 14671659].
Jiann BP, Yu CC, Su CC. Impact of introduction of sildenafil on other treatment modalities for erectile dysfunction: A study of nationwide and local hospital sales. Int J Impot Res. 2004;16(6):527-530. [pmid: 15229626].
John H, Lehmann K, Hauri D. Intraurethral prostaglandin improves quality of vacuum erection therapy. Eur Urol. 1996;29(2):224-226. [pmid: 8647152].
Juergense PH, Botev R, Wuerth D, et al. Erectile dysfunction in chronic peritoneal dialysis patients: incidence and treatment with sildenafil. Perit Dial Int. 2001;21(4):355-359. [pmid: 11587397].
Kadioglu A, Erdogru T, Tellaloglu S. Combined intracavernous injection of papaverine and stimulation (CIS) test. J Androl. 1994;15(Suppl):50S-53S. [pmid: 7721678].
Kaplan B, Ben-Rafael Z, Peled Y, et al. Oral sildenafil may reverse secondary ejaculatory dysfunction during infertility treatment. Fertility & Sterility. 1999;72(6):1144-1145. [pmid: 10593398].
Kaplan Helen S. The combined use of sex therapy and intrapenile injections in the treatment of impotence. J Sex Marital Ther. 1990;16(4):195-207. [pmid: 2079703].
Kaplan SA, Reis RB, Kohn IJ, et al. Combination therapy using oral alpha-blockers and intracavernosal injection in men with erectile dysfunction. Urology. 1998;52(5):739-743. [pmid: 9801091].
Karabulut A, Peskircioglu L, Ozkardes H, et al. Objective penile vascular response to intraurethral prostaglandin E2 (dinoprostone). Urol Int. 2001;67(2):160-162. [pmid: 11490212].
Kassouf W, Carrier S. A comparison of the International Index of Erectile Function and erectile dysfunction studies. BJU Int. 2003;91(7):667-669. [pmid: 12699481].
Katlowitz NM, Albano GJ, Morales P, et al. Potentiation of drug-induced erection with audiovisual sexual stimulation. Urology. 1993;41(5):431-434. [pmid: 8488610].
Katlowitz N, Albano GJ, Patsias G, et al. Effect of multidose intracorporeal injection and audiovisual sexual stimulation in vasculogenic impotence. Urology. 1993;42(6):695-697. [pmid: 8256402].
Kattan SA. The acceptance of satisfaction of Saudi males to vasoactive autoinjection intracavernous therapy, external negative pressure device and penile prosthesis in the treatment of erectile dysfunction. Ann Saudi Med. 2002;22(34):149-152. [pmid: 17159384].
Kaufman JM, Hatzichristou DG, Mulhall JP, et al. Impotence and chronic renal failure: a study of the hemodynamic pathophysiology. Br J Urol. 1994;151(3):612-618.
Keating GM, Scott LJ. Vardenafil: a review of its use in erectile dysfunction. Drugs. 2003;63(23):2673-2703. [pmid: 14636086].
Keating GM, Scott LJ. Spotlight on vardenafil in erectile dysfunction. Drugs Aging. 2004;21(2):135-140. [pmid: 14960129].
Kedia S, Zippe CD, Agarwal A, et al. Treatment of erectile dysfunction with sildenafil citrate (Viagra) after radiation therapy for prostate cancer. Urology. 1999;54(2):308-312. [pmid: 10443730].
Kendirci M, Bivalacqua TJ, Hellstrom WJ. Vardenafil: a novel type 5 phosphodiesterase inhibitor for the treatment of erectile dysfunction. Expert Opin Pharmacother. 2004;5(4):923-932. [pmid: 15102574].
Khan MA, Raistrick M, Mikhailidis DP, et al. MUSE: clinical experience. Current Medical Research & Opinion. 2002;18(2):64-67. [pmid: 12017211].
Khan MM, Khwaja M. Open label study of intracavernous injection of alpostadil alphadex in the treatment of erectile dysfunction. J Postgrad Med Inst. 2005;19(1):52-57.
Kim ED, McVary KT. Topical prostaglandin-E1 for the treatment of erectile dysfunction. Br J Urol. 1995;153(6):1828-1830.
Kim ED, el-Rashidy R, McVary KT. Papaverine topical gel for treatment of erectile dysfunction. Br J Urol. 1995;153(2):361-365.
Kim JM, Joh YD, Huh JD, et al. Doppler sonography of the penile cavernosal artery: comparison of intraurethral instillation and intracorporeal injection of prostaglandin E1. J Clin Ultrasound. 2001;29(5):273-278. [pmid: 11486321].
Kim NN, Christianson DW, Traish AM. Role of arginase in the male and female sexual arousal response. Br J Nutr. 2004;134(10 SUPPL.):2873S-2879S.
Kim SC, Ahn TY, Choi HK, et al. Multicenter study of the treatment of erectile dysfunction with transurethral alprostadil (MUSE) in Korea. Int J Impot Res. 2000;12(2):97-101. [pmid: 11052635].
Kim SC, Chang IH, Jeon HJ. Preference for oral sildenafil or intracavernosal injection in patients with erectile dysfunction already using intracavernosal injection for > 1 year. BJU Int. 2003;92(3):277-280. [pmid: 12887483].
Kim SC, Lee SW, Seo KK. Characteristics of pain following intracavernous injection of prostaglandin E1. J Korean Med Sci. 1997;12(4):327-331. [pmid: 9288633].
Kloner RA. Cardiovascular risk and sildenafil. [Review] [27 refs]. Am J Cardiol. 2000;86(2A):57F-61F.
Kloner RA, Zusman RM. Cardiovascular effects of sildenafil citrate and recommendations for its use. [Review] [21 refs]. Am J Cardiol. 1999;84(5B):11N-17N.
Kloner RA, Brown M, Prisant LM, et al. Effect of sildenafil in patients with erectile dysfunction taking antihypertensive therapy. Sildenafil Study Group. Am J Hypertens. 2001;14(1):70-73. [pmid: 11206684].
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil in patients on common antihypertensive therapies. [Review] [5 refs]. Am J Cardiol. 2003;92(9A):47M-57M. [pmid: 12842244].
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil. [Review] [12 refs]. Am J Cardiol. 2003;92(9A):37M-46M.
Kloner RA, Sadovsky R, Johnson EG, et al. Efficacy of tadalafil in the treatment of erectile dysfunction in hypertensive men on concomitant thiazide diuretic therapy. Int J Impot Res. 2005;17(5):450-454. [pmid: 16015377].
Kloner RA, Sadovsky R, Johnson EG, et al. Efficacy of tadalafil in the treatment of erectile dysfunction in hypertensive men on concomitant thiazide diuretic therapy. Br J Urol. 2006;175(4):1450.
Knispel HH. Penile venous surgery in impotence: results in highly selected cases. Urol Int. 1991;47(3):144-148. [pmid: 1771702].
Knispel HH, Huland H. Influence of cause on choice of therapy in 174 patients with erectile dysfunction. Br J Urol. 1992;147(5):1274-1276.
Koksal M, Ozdemir H, Kargi S, et al. The effects of sildenafil on ocular blood flow. Acta Ophthalmol Scand. 2005;83(3):355-359. [pmid: 15948790].
Kongkanand A, Opanuraks J, Tantiwongse K, et al. Evaluating dose regimens of apomorphine, an open-label study. Int J Impot Res. 2003;15(Suppl 2):10-12. [pmid: 12605235].
Kongkanand A, Ratana-Olarn K, Wuddhikarn S, et al. Evaluation of transurethal alprostadil for safety and efficacy in men with erectile dysfunction. J Med Assoc Thai. 2002;85(2):223-228. [pmid: 12081123].
Kramer-Levien D J. Papaverine—the medical implant. AUAA J 1987;7(4):13-Jun.
Kriston L, Harms A, Berner MM. A meta-regression analysis of treatment effect modifiers in trials with flexible-dose oral sildenafil for erectile dysfunction in broad-spectrum populations. Int J Impot Res. 2006;18(6):559-565. [pmid: 16688210].
Kromann-Andersen B. Intracavernosal pharmacotherapy with injection pen. Lancet. 1988;1(85756):54-59. [pmid: 2891913].
Kuba R, Pohanka M, Zakopcan J, et al. Sexual dysfunctions and blood hormonal profile in men with focal epilepsy. Epilepsia. 2006;47(12):2135-2140. [pmid: 17201714].
Kunelius P, Lukkarinenl O. Intracavernous self-injection of prostaglandin E1 in the treatment of erectile dysfunction. Int J Impot Res. 1999;11(1):21-24. [pmid: 10098949].
Kuzmarov IW, Ross D, Skamene A, et al. A sexual tune-up program as an adjunct to intracavernous pharmacotherapy. Can J Hum Sex. 1993;2(4):239-241.
Labbate Lawrence A, Grimes Jamie B, Hines Alan, et al. Bupropion treatment of serotonin reuptake antidepressant-associated sexual dysfunction. Ann Clin Psychiatry. 1997;9(4):241-245. [pmid: 9511948].
Lakin MM, Montague DK, VanderBrug Medendorp S, et al. Intracavernous injection therapy: Analysis of results and complications. Br J Urol. 1990;143(6):1138-1141.
Lal S, Kiely ME, Thavundayil JX, et al. Effect of bromocriptine in patients with apomorphine-responsive erectile impotence: an open study. J Psychiatry Neurosci. 1991;16(5):262-266. [pmid: 1797100].
Lance R, Albo M, Costabile RA, et al. Oral trazodone as empirical therapy for erectile dysfunction: a retrospective review. Urology. 1995;46(1):117-120. [pmid: 7604472].
Lane BZ, Ausmundson SJ, Butler RS, et al. Use of a visual analog scale to assess pain of injection with intracavernous injection therapy. Br J Sex Med. 2005;2(3):428-431.
Laties A, Sharlip I. Ocular safety in patients using sildenafil citrate therapy for erectile dysfunction. [Review] [81 refs]. Br J Sex Med. 2006;3(1):12-27.
Laties AM, Zrenner E. Viagra (sildenafil citrate) and ophthalmology. Progress in Retinal & Eye Research. 2002;21(5):485-506. [pmid: 12207947].
Laties A M, Fraunfelder F T, Flach A J et al. Ocular safety of Viagra, (sildenafil citrate). Trans Am Ophthalmol Soc 1999;97(pp 115–128):-128.
Lawless C, Cree J. Oral medications in the management of erectile dysfunction. [Review] [15 refs]. J Am Board Fam Pract. 1998;11(4):307-314. [pmid: 9719353].
Lawless C, Force RW. Sildenafil for erectile dysfunction. J Fam Pract. 1998;47(2):97-98. [pmid: 9722794].
Lawrence IG, Price DE, Howlett TA, et al. Correcting impotence in the male dialysis patient: experience with testosterone replacement and vacuum tumescence therapy. Am J Kidney Dis. 1998;31(2):313-319. [pmid: 9469503].
Le Bon O, Lion K, Verbanck P, et al. Fluparoxan in male erectile disorder: A case report. Yakubutsu Seishin Kodo. 1995;9(1):67-68.
Lea AP, Bryson HM, Balfour JA. Intracavernous alprostadil. A review of its pharmacodynamic and pharmacokinetic properties and therapeutic potential in erectile dysfunction. [Review] [123 refs]. Drugs Aging. 1996;8(1):56-74. [pmid: 8785470].
Lee J, Pommerville P, Brock G, et al. Physician-rated patient preference and patient- and partner-rated preference for tadalafil or sildenafil citrate: results from the Canadian ‘Treatment of Erectile Dysfunction’ observational study. BJU Int. 2006;98(3):623-629. [pmid: 16925764].
Lee WR. The role of androgen deprivation therapy combined with prostate brachytherapy. [Review] [31 refs]. Urology. 2002;60(3:Suppl 1):Suppl-44.
Levine LA, Latchamsetty KC. Treatment of erectile dysfunction in patients with Peyronie's disease using sildenafil citrate. Int J Impot Res. 2002;14(6):478-482. [pmid: 12494281].
Levitt EE, Mulcahy JJ. The effect of intracavernosal injection of papaverine hydrochloride on orgasm latency. Br J Sex Med. 1995;21(1):39-42.
Lewis RL, Sadovsky R, Eardley I, et al. The efficacy of tadalafil in clinical populations. Br J Sex Med. 2005;2(4):517-531.
Lewis RW. Intraurethral and topical agents. Med Actual. 2000;36(23):113-119.
Li MK, Lim PH, Wong MY, et al. Transurethral alprostadil for the treatment of erectile dysfunction: results of a multicentre trial. Ann Acad Med Singapore. 2000;29(6):727-731. [pmid: 11269978].
Lim PH, Ng FC. Erectile dysfunction in Singapore men: presentation, diagnosis, treatment and results. Ann Acad Med Singapore. 1992;21(2):248-253. [pmid: 1519896].
Lim PHC, Man KL, Foo CN, et al. Clinical efficacy and safety of sildenafil citrate (Viagra) in a multi-racial population in Singapore: A retrospective study of 1520 patients. Int J Urol. 2002;9(6):308-315. [pmid: 12110094].
Liu LC, Wu CC, Liu LH, et al. Comparison of the effects of papaverine versus prostaglandin E1 on penile blood flow by color duplex sonography. Eur Urol. 1991;19(1):49-53. [pmid: 2007418].
Livi U, Faggian G, Sorbara C, et al. Use of prostaglandin E1 in the treatment of sexual impotence after heart transplantation: initial clinical experience. Journal of Heart & Lung Transplantation. 1993;12(3):484-486. [pmid: 8329422].
Lombardo T, Giammusso B, Frontini V, et al. Thalassaemic men affected by erectile dysfunction treated with transurethral alprostadil: case report. Hum Reprod. 2000;15(11):2375-2378. [pmid: 11056136].
Long RL, Sherman LS, Lombardi TJ. A goal-oriented, cost-effective approach to the diagnosis and treatment of 24 male erectile dysfunction. [Review] [24 refs]. J Ky Med Assoc. 1995;93(11):500-508. [pmid: 8778212].
Lottman PE, Hendriks JC, Vruggink PA, et al. The impact of marital satisfaction and psychological counselling on the outcome of ICI-treatment in men with ED. Int J Impot Res. 1998;10(2):83-87. [pmid: 9647943].
Lowentritt BH, Scardino PT, Miles BJ, et al. Sildenafil citrate after radical retropubic prostatectomy. Br J Urol. 1999;162(5):1614-1617.
Lowy M, Collins S, Bloch M, et al. Quality of erection questionnaire correlates: change in erection quality with erectile function, hardness, and psychosocial measures in men treated with sildenafil for erectile dysfunction. Br J Sex Med. 2007;4(1):83-92.
Lue TF. Impotence after radical pelvic surgery: physiology and management. [Review] [56 refs]. Urol Int. 1991;46(3):259-265. [pmid: 1926639].
Lukkarinen O, Tonttila P, Hellstrom P, et al. Non-prosthetic surgery in the treatment of erectile dysfunction. A retrospective study of 45 impotent patients in the University of Oulu. Scandinavian Journal of Urology & Nephrology. 1998;32(1):42-46. [pmid: 9561573].
Lundberg L, Olsson JO, Kihl B. Long-term experience of self-injection therapy with prostaglandin E1 for erectile dysfunction. Scand J Urol Nephrol. 1996;30(5):395-397. [pmid: 8936629].
Lunenfeld B. Androgen therapy in the aging male. [Review] [110 refs]. World J Urol. 2003;21(5):292-305. [pmid: 14576959].
Magoha GA. Sildenafil (Viagra) in the treatment of male erectile dysfunction in Nairobi. East Afr Med J. 2000;77(2):76-79. [pmid: 10774079].
Manecke RG, Mulhall JP. Medical treatment of erectile dysfunction. [Review] [69 refs]. Ann Med. 1999;31(6):388-398. [pmid: 10680853].
Maniam P, Seftel AD, Corty EW, et al. Nocturnal penile tumescence activity unchanged after long-term intracavernous injection therapy. Br J Urol. 2001;165(3):830-832.
Mansi MK, Alkhudair WK, Huraib S. Treatment of erectile dysfunction after kidney transplantation with intracavernosal self-injection of prostaglandin E1. Br J Urol. 1998;159(6):1927-1930.
Marberger M, Roehrborn CG, Marks LS, et al. Relationship among serum testosterone, sexual function, and response to treatment in men receiving dutasteride for benign prostatic hyperplasia. Journal of Clinical Endocrinology & Metabolism. 2006;91(4):1323-1328. [pmid: 16434455].
Mark SD, Keane TE, Vandemark RM, et al. Impotence following pelvic fracture urethral injury: incidence, aetiology and management. Br J Urol. 1995;75(1):62-64. [pmid: 7850299].
Markou S, Perimenis P, Gyftopoulos K, et al. Vardenafil (Levitra) for erectile dysfunction: a systematic review and meta-analysis of clinical trial reports. Int J Impot Res. 2004;16(6):470-478. [pmid: 15229625].
Marks LS, Duda C, Dorey FJ, et al. Treatment of erectile dysfunction with sildenafil.[see comment]. Urology. 1999;53(1):19-24. [pmid: 9886582].
Marshall GA, Breza J, Lue TF. Improved hemodynamic response after long-term intracavernous injection for impotence. Urology. 1994;43(6):844-848. [pmid: 8197648].
Martin-Morales A, Haro JM, Beardsworth A, et al. Therapeutic effectiveness and patient satisfaction after 6 months of treatment with tadalafil, sildenafil, and vardenafil: results from the erectile dysfunction observational study (EDOS). Eur Urol. 2007;51(2):541-550. [pmid: 17084518].
Martin-Morales A, Moncada Iribarren I, Cruz Navarro N, et al. [Efficacy and safety of two dosing regimens with Tadalafil in Spanish men with erectile dysfunction: results from the SURE study in 14 European countries]. Actas Urol Esp. 2006;30(8):791-800. [pmid: 17078576].
Martinez R, Puigvert A, Pomerol JM, et al. Clinical experience with apomorphine hydrochloride: the first 107 patients. Br J Urol. 2003;170(6:Pt 1):t-5.
Martinez-Jabaloyas JM, Gil-Salom M, Villamon-Fort R, et al. Prognostic factors for response to sildenafil in patients with erectile dysfunction. Eur Urol. 2001;40(6):641-647. [pmid: 11805410].
Martinez-Pineiro L, Cortes R, Cuervo E, et al. Prospective comparative study with intracavernous sodium nitroprusside and prostaglandin E1 in patients with erectile dysfunction. Eur Urol. 1998;34(4):350-354. [pmid: 9748684].
Matthew AG, Goldman A, Trachtenberg J, et al. Sexual dysfunction after radical prostatectomy: Prevalence, treatments, restricted use of treatments and distress. Br J Urol. 2005;174(6):2105-2110.
Maytom MC, Derry FA, Dinsmore WW, et al. A two-part pilot study of sildenafil (VIAGRA) in men with erectile dysfunction caused by spinal cord injury. Spinal Cord. 1999;37(2):110-116. [pmid: 10065749].
McClure RD. Endocrine evaluation and therapy of erectile dysfunction. [Review] [77 refs]. Urol Clin North Am. 1988;15(1):53-64. [pmid: 3278476].
McClure RD, Oses R, Ernest ML. Hypogonadal impotence treated by transdermal testosterone. Urology. 1991;37(3):224-228. [pmid: 2000678].
McConnell JD, Roehrborn CG, Bautista OM, et al. The Long-Term Effect of Doxazosin, Finasteride, and Combination Therapy on the Clinical Progression of Benign Prostatic Hyperplasia. N Engl J Med. 2003;349(25):2387-2398. [pmid: 14681504].
McCullough AR, Barada JH, Fawzy A, et al. Achieving treatment optimization with sildenafil citrate (Viagra) in patients with erectile dysfunction. Urology. 2002;60(2 Suppl 2):28-38. [pmid: 12414331].
McCullough AR, Carson CC, Hatzichristou D. A prospective study of the beneficial effects of dose optimization and customized instructions on patient satisfaction with sildenafil citrate (Viagra) for erectile dysfunction. Urology. 2006;68(3 Suppl):38-46. [pmid: 17011374].
McMahon C. Comparison of erectile responses to differing doses of prostaglandin PGE1 in an attempt to standardise pharmacological diagnosis of impotence. Journal of Assisted Reproduction & Genetics 1992;9265A
McMahon C. Efficacy and safety of daily tadalafil in men with erectile dysfunction previously unresponsive to on-demand tadalafil. Br J Sex Med. 2004;1(3):292-300.
McMahon CG. High dose sildenafil citrate as a salvage therapy for severe erectile dysfunction. Int J Impot Res. 2002;14(6):533-538. [pmid: 12494291].
McMahon CG. An attempt to standardize the pharmacological diagnostic screening of vasculogenic impotence with prostaglandin E1. Int J Impot Res. 1995;7(2):83-90. [pmid: 7496445].
McMahon CG. Topiglan: MacroChem. Curr Opin Investig Drugs. 2002;3(4):602-606.
McMahon CG. A pilot study of the role of intracavernous injection of vasoactive intestinal peptide (VIP) and phentolamine mesylate in the treatment of erectile dysfunction. Int J Impot Res. 1996;8(4):233-236. [pmid: 8981173].
McMahon CG. Priapism associated with concurrent use of phosphodiesterase inhibitor drugs and intracavernous injection therapy. Int J Impot Res. 2003;15(5):383-384. [pmid: 14562142].
McMahon CG, Samali R, Johnson H. Efficacy, safety and patient acceptance of sildenafil citrate as treatment for erectile dysfunction. Br J Urol. 2000;164(4):1192-1196.
McMahon CG, Samali R, Johnson H. Treatment of intracorporeal injection nonresponse with sildenafil alone or in combination with triple agent intracorporeal injection therapy. Br J Urol. 1997;162(6):1992-1997.
McMahon C, Lording D, Stuckey B, et al. Vardenafil improved erectile function in a “real-life” broad population study of men with moderate to severe erectile dysfunction in Australia and New Zealand. Br J Sex Med. 2006;3(5):892-900.
McVary KT, Polepalle S, Riggi S, et al. Topical prostaglandin E1 SEPA gel for the treatment of erectile dysfunction. Br J Urol. 1999;162(3 Pt 1):732.
Mealy NE. Alprostadil cream. Drugs of the Future. 2004;29(6):626-627.
Mealy NE, Bayes M. PT-141. Drugs of the Future. 2004;29(11):1177.
Mehdiyev T V. Intracavernous injection probe of vasoactive preparations in the diagnosis of erectile dysfunctions in patients with diabetes mellitus. Azerbaidzhanskii Meditsinskii Zhurnal 2002;(pp 17–19):-19.
Meinhardt W, de la, Fuente RB, et al. Prostaglandin E1 with phentolamine for the treatment of erectile dysfunction. Int J Impot Res. 1996;8(1):5-7. [pmid: 8735187].
Meinhardt W, Nijeholt AA, Kropman RF, et al. Comparison of a mixture of papaverine, phentolamine and prostaglandin E1 with other intracavernous injections. Eur Urol. 1994;26(4):319-321. [pmid: 7713130].
Mellinger BC, Fried JJ, Darracott Vaughan. Papaverine-induced penile blood flow acceleration in impotent men measured by duplex scanning. Br J Urol. 1990;144(4):897-899.
Merrick GS, Butler WM, Lief JH, et al. Efficacy of sildenafil citrate in prostate brachytherapy patients with erectile dysfunction. Urology. 1999;53(6):1112-1116. [pmid: 10367837].
Metawea B, El-Nashar AR, Gad-Allah A, et al. Intracavernous papaverine/phentolamine-induced priapism can be accurately predicted with color Doppler ultrasonography. Urology. 2005;66(4):858-860. [pmid: 16230153].
Meyhoff HH, Rosenkilde P, Bodker A. Non-invasive management of impotence with transcutaneous nitroglycerin. Br J Urol. 1992;69(1):88-90. [pmid: 1737261].
Mikhail N. Does Testosterone Have a Role in Erectile Function?. Am J Med. 2006;119:373-382. [pmid: 16651047].
Millard RJ, Stricker PD, Lynch WJ, et al. Risks of self-injection therapy for impotence. Med J Aust. 1996;165(2):117-118. [pmid: 8692055].
Miller N, Smolkin ME, Bissonette E, et al. Undetectable prostate specific antigen at 6–12 months: a new marker for early success in hormonally treated patients after prostate brachytherapy. Cancer. 2005;103(12):2499-2506. [pmid: 15852361].
Mills TM, Lewis RW. The role of androgens in the erectile response: A 1999 perspective. Mol Urol. 1999;3(2):75-80. [pmid: 10851308].
Mirone VG, Stief CG. Efficacy of apomorphine SL in erectile dysfunction.[erratum appears in BJU Int 2002 Jan;89(1):140]. [Review] [11 refs]. BJU Int. 2001;88(Suppl 3):25-29. [pmid: 11578276].
Mirone V, Imbimbo C, Fabrizio F, et al. Ketanserin plus prostaglandin E1 (PGE-1) as intracavernosal therapy for patients with erectile dysfunction unresponsive to PGE-1 alone. Br J Urol. 1996;77(5):736-739. [pmid: 8689122].
Mirone V, Palmieri A, Cucinotta D, et al. Flexible-dose vardenafil in a community-based population of men affected by erectile dysfunction: a 12-week open-label, multicenter trial. Br J Sex Med. 2005;2(6):842-847.
Mittleman MA, Glasser DB, Orazem J. Clinical trials of sildenafil citrate (Viagra) demonstrate no increase in risk of myocardial infarction and cardiovascular death compared with placebo. Int J Clin Pract. 2003;57(7):597-600. [pmid: 14529061].
Mittleman MA, Maclure M, Glasser DB. Evaluation of acute risk for myocardial infarction in men treated with sildenafil citrate. Am J Cardiol. 2005;96(3):443-446. [pmid: 16054479].
Moemen MN, Hamed HA, Kamel II, et al. Clinical and sonographic assessment of the side effects of intracavernous injection of vasoactive substances. Int J Impot Res. 2004;16(2):143-145. [pmid: 15014552].
Moncada I, Jara J, Subira D, et al. Efficacy of sildenafil citrate at 12 hours after dosing: re-exploring the therapeutic window. Eur Urol. 2004;46(3):357-360. [pmid: 15306108].
Montorsi F, Althof SE. Partner responses to sildenafil citrate (Viagra) treatment of erectile dysfunction. Urology. 2004;63(4):762-767. [pmid: 15072897].
Montorsi F, McCullough A. Efficacy of sildenafil citrate in men with erectile dysfunction following radical prostatectomy: A systematic review of clinical data. Br J Sex Med. 2005;2(5):658-667.
Montorsi F, Althof SE, Sweeney M, et al. Treatment satisfaction in patients with erectile dysfunction switching from prostaglandin E(1) intracavernosal injection therapy to oral sildenafil citrate. Int J Impot Res. 2003;15(6):444-449. [pmid: 14671665].
Montorsi F, Briganti A, Salonia A, et al. Can Phosphodiesterase Type 5 Inhibitors Cure Erectile Dysfunction?. Eur Urol. 2006;49(6):979-986. [pmid: 16431013].
Montorsi F, Guazzoni G, Barbieri L, et al. The effect of intracorporeal injection plus genital and audiovisual sexual stimulation versus second injection on penile color Doppler sonography parameters. Br J Urol. 1996;155(2):536-540.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Effectiveness and safety of multidrug intracavernous therapy for vasculogenic impotence. Urology. 1993;42(5):554-558. [pmid: 7694416].
Montorsi F, Guazzoni G, Bergamaschi F, et al. Four-drug intracavernous therapy for impotence due to corporeal veno-occlusive dysfunction. Br J Urol. 1993;149(5 Pt 2):1291-1295.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Intracavernous vasoactive pharmacotherapy: the impact of a new self-injection device.[see comment]. Br J Urol. 1993;150(6):1829-1832.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Clinical reliability of multi-drug intracavernous vasoactive pharmacotherapy for diabetic impotence. Acta Diabetol Lat. 1994;31(1):1-5.
Montorsi F, Hellstrom WJ, Valiquette L, et al. Vardenafil provides reliable efficacy over time in men with erectile dysfunction. Urology. 2004;64(6):1187-1195. [pmid: 15596195].
Montorsi F, Perani D, Anchisi D, et al. Apomorphine-induced brain modulation during sexual stimulation: a new look at central phenomena related to erectile dysfunction. Int J Impot Res. 2003;15(3):203-209. [pmid: 12904807].
Montorsi F, Salonia A, Briganti A, et al. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol. 2005;47(5):612-621. [pmid: 15826752].
Montorsi F, Verheyden B, Meuleman E, et al. Long-term safety and tolerability of tadalafil in the treatment of erectile dysfunction. Eur Urol. 2004;45(3):339-344. [pmid: 15036680].
Moore R A, Derry S, McQuay H J. Indirect comparison of interventions using published randomised trials: systematic review of PDE-5 inhibitors for erectile dysfunction. [Review][77 refs]. BMC Urol 2005;518
Moore R A, Edwards J E, McQuay H J. Sildenafil (Viagra) for male erectile dysfunction: a meta-analysis of clinical trial reports. BMC Urol. 2002;26
Morales A, Gingell C, Collins M, et al. Clinical safety of oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):69-73. [pmid: 9647940].
Morales A, Johnston B, Heaton JP, et al. Testosterone supplementation for hypogonadal impotence: assessment of biochemical measures and therapeutic outcomes. Br J Urol. 1997;157(3):849-854.
Morales A, Johnston B, Heaton JW, et al. Oral androgens in the treatment of hypogonadal impotent men.[see comment]. Br J Urol. 1994;152(4):1115-1118.
Morgentaler A, Barada J, Niederberger C, et al. Efficacy and safety of tadalafil across ethnic groups and various risk factors in men with erectile dysfunction: Use of a novel noninferiority study design. Br J Sex Med. 2006;3(3):492-503.
Mulhall JP. Deciphering erectile dysfunction drug trials. [Review] [35 refs]. Br J Urol. 2003;170(2 Pt 1):353-358.
Mulhall JP. Sublingual apomorphine for the treatment of erectile dysfunction. [Review] [22 refs]. Expert Opin Investig Drugs. 2002;11(2):295-302.
Mulhall JP, Bukofzer S, Edmonds AL, et al. An open-label, uncontrolled dose-optimization study of sublingual apomorphine in erectile dysfunction. Clin Ther. 2001;23(8):1260-1271. [pmid: 11558862].
Mulhall JP, Guhring P, Parker M, et al. Assessment of the impact of sildenafil citrate on lower urinary tract symptoms in men with erectile dysfunction. Br J Sex Med. 2006;3(4):662-667.
Mulhall JP, Jahoda AE, Ahmed A, et al. Analysis of the consistency of intraurethral prostaglandin E(1) (MUSE) during at-home use. Urology. 2001;58(2):262-266. [pmid: 11489714].
Mulhall JP, Jahoda AE, Cairney M, et al. The causes of patient dropout from penile self-injection therapy for impotence. Br J Urol. 1999;162(4):1291-1294.
Mulhall JP, Jahoda A, Aviv N, et al. The impact of sildenafil citrate on sexual satisfaction profiles in men with a penile prosthesis in situ. BJU Int. 2004;93(1):97-99. [pmid: 14678377].
Mulhall JP, Land S, Parker M, et al. The use of an erectogenic pharmacotheraphy regimen following radical prostatectomy improves recovery of spontaneous erectile function. Br J Sex Med. 2005;2(4):532-542.
Mulhall JP, Levine LA, Junemann KP. Erection hardness: a unifying factor for defining response in the treatment of erectile dysfunction. [Review] [37 refs]. Urology. 2006;68(3 Suppl):17-25. [pmid: 17011372].
Mulhall J, Barnas J, Aviv N, et al. Sildenafil citrate response correlates with the nature and the severity of penile vascular insufficiency. Br J Sex Med. 2005;2(1):104-108.
Muller MJ, Benkert O. Lower self-reported depression in patients with erectile dysfunction after treatment with sildenafil. J Affect Disord. 2001;66(23):255-261. [pmid: 11578679].
Muller MJ, Ruof J, Graf-Morgenstern M, et al. Quality of partnership in patients with erectile dysfunction after sildenafil treatment. Pharmacopsychiatry. 2001;34(3):91-95. [pmid: 11434405].
Murat Basar M, Tekdogan UY, Yilmaz E, et al. The efficacy of sildenafil in different etiologies of erectile dysfunction. International Urology & Nephrology. 2001;32(3):403-407. [pmid: 11583361].
Murphy AM, O'Leary M. Failure of the Ambicor inflatable penile prosthesis to deflate. Int J Impot Res. 2005;17(3):291-292. [pmid: 15605073].
Murphy JC, Srinivas S, Terris MK. Flutamide administration at 500 mg daily has similar effects on serum testosterone to 750 mg daily. J Androl. 2004;25(4):630-634. [pmid: 15223852].
Mydlo JH, Viterbo R, Crispen P. Use of combined intracorporal injection and a phosphodiesterase-5 inhibitor therapy for men with a suboptimal response to sildenafil and/or vardenafil monotherapy after radical retropubic prostatectomy. BJU Int. 2005;95(6):843-846. [pmid: 15794795].
Mydlo JH, Volpe MA, MacChia RJ. Results from different patient populations using combined therapy with alprostadil and sildenafil: predictors of satisfaction. BJU Int. 2000;86(4):469-473. [pmid: 10971274].
Nagai A, Kusumi N, Tsuboi H, et al. Intracavernous injection of prostaglandin E1 is effective in patients with erectile dysfunction not responding to phosphodiseterase 5 inhibitors. Acta Med Okayama. 2005;59(6):279-280. [pmid: 16418771].
Nalesnik JG, Jones L, Kraus SR. Group B streptococcal septicemia following intracavernous injection therapy for erectile dysfunction in diabetes. Br J Urol. 2004;172(1):151-152.
Nandipati K, Raina R, Agarwal A, et al. Early combination therapy: intracavernosal injections and sildenafil following radical prostatectomy increases sexual activity and the return of natural erections. Int J Impot Res. 2006;18(5):446-451. [pmid: 16482200].
Naude JH, Le Roux PJ. Topical treatment of erectile dysfunction did not show results.[comment]. BMJ. 1998;316(7140):1318. [pmid: 9554911].
Nehra A, Blute ML, Barrett DM, et al. Rationale for combination therapy of intraurethral prostaglandin E(1) and sildenafil in the salvage of erectile dysfunction patients desiring noninvasive therapy. Int J Impot Res. 2002;14(Suppl 1):38-42. [pmid: 11896476].
Nessel Mark A. Yohimbine and pentoxifylline in the treatment of erectile dysfunction. Am J Psychiatry. 1994;151(3):453.
Nurnberg H G, Hensley P L. Sildenafil citrate for the management of antidepressant-associated erectile dysfunction. Hillside J Clin Psychiatry 2003;64Suppl-5.
Nurnberg HG, Fava M, Gelenberg AJ, et al. Open-label sildenafil treatment of partial and non-responders to double-blind treatment in men with antidepressant-associated sexual dysfunction. Int J Impot Res. 2007;19(2):167-175. [pmid: 16871270].
Nurnberg HG, Gelenberg A, Hargreave TB, et al. Efficacy of sildenafil citrate for the treatment of erectile dysfunction in men taking serotonin reuptake inhibitors. Am J Psychiatry. 2001;158(11):1926-1928. [pmid: 11691705].
Nurnberg HG, Lauriello J, Hensley PL, et al. Sildenafil for iatrogenic serotonergic antidepressant medication-induced sexual dysfunction in 4 patients.[see comment]. Hillside J Clin Psychiatry. 1999;60(1):33-35.
Nurnberg HG, Seidman SN, Gelenberg AJ, et al. Depression, antidepressant therapies, and erectile dysfunction: clinical trials of sildenafil citrate (Viagra) in treated and untreated patients with depression. Urology. 2002;60(2 Suppl 2):58-66. [pmid: 12414334].
Nurnberg H, George Hensley, Paula L, et al. Sildenafil in the treatment of sexual dysfunction induced by selective serotonin reuptake inhibitors: An overview. [References]. CNS Drugs. 2000;13(5):321-335.
O'Sullivan JD, Hughes AJ. Apomorphine-induced penile erections in Parkinson's disease. Mov Disord. 1998;13(3):536-539. [pmid: 9613749].
Ochiai A, Naya Y, Soh J, et al. Efficacy of sildenafil as the first-step therapeutic tool for Japanese patients with erectile dysfunction. Int J Impot Res. 2005;17(4):339-342. [pmid: 15829991].
Ogura K, Ichioka K, Terada N, et al. Role of sildenafil citrate in treatment of erectile dysfunction after radical retropubic prostatectomy. Int J Urol. 2004;11(3):159-163. [pmid: 15009364].
Ohebshalom M, Mulhall JP. Transdermal and topical pharmacotherapy for male sexual dysfunction. Expert Opinion on Drug Delivery. 2005;2(1):115-120. [pmid: 16296739].
Ohebshalom M, Parker M, Guhring P, et al. The efficacy of sildenafil citrate following radiation therapy for prostate cancer: temporal considerations. Br J Urol. 2005;174(1):258-262.
Opsomer RJ, Wese FX, De Groote P, et al. The external vacuum device in the management of erectile dysfunction. Acta Urol Belg. 1997;65(4):13-16. [pmid: 9497591].
Ormrod D, Easthope SE, Figgitt DP. Vardenafil.[erratum appears in Drugs Aging 2002;19(11):886]. [Review] [30 refs]. Drugs Aging. 2002;19(3):217-227. [pmid: 12027779].
Osegbe D N, Shittu O B, Aghaji A E et al. Sildenafil citrate (Viagra) for the treatment of erectile dysfunction in Nigerian men. Int J Impot Res 2003;15Suppl-8.
Osterloh IH, Riley A. Clinical update on sildenafil citrate. [Review] [58 refs]. Br J Clin Pharmacol. 2002;53(3):219-223. [pmid: 11874383].
Osterloh I H, Collins M, Wicker P et al. Sildenafil citrate (VIAGRA): overall safety profile in 18 double-blind, placebo controlled, clinical trials. [Review][0 refs]. Int J Clin Pract 1999;Supplement.102–105.
Padma-Nathan H, Yeager JL. An integrated analysis of alprostadil topical cream for the treatment of erectile dysfunction in 1732 patients. Urology. 2006;68(2):386-391. [pmid: 16904458].
Padma-Nathan H, Goldstein I, Klimberg I, et al. Long-term safety and efficacy of oral phentolamine mesylate (Vasomax) in men with mild to moderate erectile dysfunction. Int J Impot Res. 2002;14(4):266-270. [pmid: 12152116].
Padma-Nathan H, McMurray JG, Pullman WE, et al. On-demand IC351 (Cialis) enhances erectile function in patients with erectile dysfunction. Int J Impot Res. 2001;13(1):2-9. [pmid: 11313831].
Padma-Nathan H, Montorsi F, Giuliano F, et al. Vardenafil restores erectile function to normal range in men with erectile dysfunction. Br J Sex Med. 2007;4(1):152-161.
Pagani E, Glina S, Puech-Leao P, et al. Anxiety and high plasma catecholamines do not impair pharmaco-induced erection of psychogenic erectile dysfunctional patients. Int J Impot Res. 2003;15(4):282-286. [pmid: 12934057].
Pagani E, Puech-Leao P, Glina S, et al. The value of a second injection on the pharmaco-induced erection test. Int J Impot Res. 1997;9(3):167-168. [pmid: 9315495].
Pallas James, Levine Stephen B, Althof Stanley E, et al. A study using Viagra in a mental health practice. [References]. J Sex Marital Ther. 2000;26(1):41-50. [pmid: 10693115].
Palumbo F, Bettocchi C, Selvaggi FP, et al. Sildenafil: efficacy and safety in daily clinical experience. Eur Urol. 2001;40(2):176-180. [pmid: 11528195].
Pangkahila WI. Evaluation of transurethral application of alprostadil for erectile dysfunction in Indonesians. Asian J Androl. 2000;2(3):233-236. [pmid: 11225984].
Park K, Ku JH, Kim SW, et al. Risk factors in predicting a poor response to sildenafil citrate in elderly men with erectile dysfunction. BJU Int. 2005;95(3):366-370. [pmid: 15679795].
Parkerson George RJ, Willke Richard J, Hays Ron D. An international comparison of the reliability and responsiveness of the Duke Health Profile for measuring health-related quality of life of patients treated with alprostadil for erectile dysfunction. Med Care. 1999;37(1):56-67. [pmid: 10413393].
Penninga E, Jensen BA, Hansen PB, et al. Anagrelide treatment in 52 patients with chronic myeloproliferative diseases. Clinical & Laboratory Haematology. 2004;26(5):335-340. [pmid: 15485463].
Perimenis P, Athanasopoulos A, Geramoutsos I, et al. The incidence of pharmacologically induced priapism in the diagnostic and therapeutic management of 685 men with erectile dysfunction. Urol Int. 2001;66(1):27-29. [pmid: 11150947].
Perimenis P, Athanasopoulos A, Papathanasopoulos P, et al. Gabapentin in the management of the recurrent, refractory, idiopathic priapism. Int J Impot Res. 2004;16(1):84-85. [pmid: 14963477].
Perimenis P, Markou S, Gyftopoulos K, et al. Switching from long-term treatment with self-injections to oral sildenafil in diabetic patients with severe erectile dysfunction. Eur Urol. 2002;41(4):387-391. [pmid: 12074808].
Pescatori ES, Calpista A, Artibani W, et al. Self-injection devices for intracavernosal pharmacotherapy: operational classification and safety considerations. Int J Impot Res. 1996;8(2):53-57. [pmid: 8858390].
Peskircioglu L, Tekin MI, Demirag A, et al. Evaluation of erectile function in renal transplant recipients. Transplant Proc. 1998;30(3):747-749. [pmid: 9595082].
Peterson CA, Bennett AH, Hellstrom WJ, et al. Erectile response to transurethral alprostadil, prazosin and alprostadil-prazosin combinations. Br J Urol. 1998;159(5):1523-1527.
Petrov VI, Vekel'yan AS, Martyushev AV, et al. Impaza and Sildenafil: Comparison of Clinical Effectiveness in Patients with Erectile Dysfunction. Bull Exp Biol Med. 2003;135–136(Suppl 1):150-151.
Petty R, Angwin R. How real is the male menopause?. Br J Gen Pract. 2004;248(1659):452-456.
Pierce LJ, Whittington R, Hanno PM, et al. Pharmacologic erection with intracavernosal injection for men with sexual dysfunction following irradiation: a preliminary report. Int J Radiat Oncol Biol Phys. 1991;21(5):1311-1314. [pmid: 1938529].
Pohanka M, Kanovsky P, Bares M, et al. The long-lasting improvement of sexual dysfunction in patients with advanced, fluctuating Parkinson's disease induced by pergolide: evidence from the results of an open, prospective, one-year trial. Parkinsonism Relat Disord. 2005;11(8):509-512. [pmid: 15994112].
Pohanka M, Kanovsky P, Bares M, et al. Pergolide mesylate can improve sexual dysfunction in patients with Parkinson's disease: the results of an open, prospective, 6-month follow-up. Eur J Neurol. 2004;11(7):483-488. [pmid: 15257688].
Polak K, Wimpissinger B, Berisha F, et al. Effects of sildenafil on retinal blood flow and flicker-induced retinal vasodilatation in healthy subjects. Invest Ophthalmol Vis Sci. 2003;44(11):4872-4876. [pmid: 14578411].
Pomara G, Morelli G, Montorsi F, et al. Re: Montorsi F, Salonia A, Briganti A, Barbieri L, Zanni G, Surdi N, Cestari A, Montorsi P, Rigatti P. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol 2005;47:612–21 (multiple letters). Eur Urol. 2005;48(2):345-346. [pmid: 15939526].
Pomara G, Morelli G, Pomara S, et al. Cardiovascular parameter changes in patients with erectile dysfunction using pde-5 inhibitors: a study with sildenafil and vardenafil. J Androl. 2004;25(4):625-629. [pmid: 15223851].
Pommerville P. Drug treatments for erectile dysfunction: An update. Geriatrics and Aging. 2004;7(6):10-16.
Porst H. IC351 (tadalafil, Cialis): update on clinical experience. [Review][12 refs]. Int J Impot Res 2002;14Suppl-64.
Porst H. Transurethral alprostadil with MUSE (medicated urethral system for erection) vs intracavernous alprostadil—a comparative study in 103 patients with erectile dysfunction. Int J Impot Res. 1997;9(4):187-192. [pmid: 9442415].
Porst H. Phosphodiesterase type-5 inhibitors: A critical comparative analysis. Eau Update Series. 2004;2(2):56-63.
Porst H, Lungimayr G, utsch-osterreichische STEA. [Efficacy and tolerability of vardenafil within the time window of 6 hours after administration and beyond. Results of a clinical study carried out in 233 urological offices]. MMW Fortschr Med. 2005;147(Suppl 1):27-32. [pmid: 16739369].
Potempa AJ, Ulbrich E, Bernard I, et al. Efficacy of vardenafil in men with erectile dysfunction: a flexible-dose community practice study. Eur Urol. 2004;46(1):73-79. [pmid: 15183550].
Pradeep C, Car N, Metelko Z. Impotence in diabetic men. Diabetol Croat. 1996;25(2):61-68.
Price D. Sildenafil citrate (Viagra) efficacy in the treatment of erectile dysfunction in patients with common concomitant conditions. Sildenafil Study Group. Int J Clin Pract 1999;Supplement.102–103.
Price DE, Cooksey G, Jehu D, et al. The management of impotence in diabetic men by vacuum tumescence therapy. Diabet Med. 1991;8(10):964-967. [pmid: 1838050].
Prieto Castro RM, nglada Curado FJ, Regueiro Lopez JC, et al. Treatment with sildenafil citrate in renal transplant patients with erectile dysfunction. BJU Int. 2001;88(3):241-243. [pmid: 11488737].
Priyadarshi S. Oral terbutaline in the management of pharmacologically induced prolonged erection. Int J Impot Res. 2004;16(5):424-426. [pmid: 14999218].
Pryor J. Vardenafil: update on clinical experience. [Review][10 refs]. Int J Impot Res 2002;14Suppl-9.
Purvis K, Brekke I, Christiansen E. Determinants of satisfactory rigidity after intracavernosal injection with prostaglandin E1 in men with erectile failure. Int J Impot Res. 1996;8(1):9-16. [pmid: 8735188].
Radomski SB, Herschorn S, Rangaswamy S. Topical minoxidil in the treatment of male erectile dysfunction. Br J Urol. 1994;151(5):1225-1226.
Raffaele R, Vecchio I, Giammusso B, et al. Efficacy and safety of fixed-dose oral sildenafil in the treatment of sexual dysfunction in depressed patients with idiopathic Parkinson's disease. Eur Urol. 2002;41(4):382-386. [pmid: 12074807].
Raina R, Agarwal A, Allamaneni SS, et al. Sildenafil citrate and vacuum constriction device combination enhances sexual satisfaction in erectile dysfunction after radical prostatectomy. Urology. 2005;65(2):360-364. [pmid: 15708053].
Raina R, Agarwal A, Goyal KK, et al. Long-term potency after iodine-125 radiotherapy for prostate cancer and role of sildenafil citrate. Urology. 2003;62(6):1103-1108. [pmid: 14665364].
Raina R, Lakin MM, Agarwal A, et al. Long-term intracavernous therapy responders can potentially switch to sildenafil citrate after radical prostatectomy. Urology. 2004;63(3):532-537. [pmid: 15028452].
Raina R, Lakin MM, Agarwal A, et al. Efficacy and factors associated with successful outcome of sildenafil citrate use for erectile dysfunction after radical prostatectomy. Urology. 2004;63(5):960-966. [pmid: 15134989].
Raina R, Lakin MM, Agarwal A, et al. Long-term effect of sildenafil citrate on erectile dysfunction after radical prostatectomy: 3-year follow-up. Urology. 2003;62(1):110-115. [pmid: 12837433].
Raina R, Lakin MM, Thukral M, et al. Long-term efficacy and compliance of intracorporeal (IC) injection for erectile dysfunction following radical prostatectomy: SHIM (IIEF-5) analysis. Int J Impot Res. 2003;15(5):318-322. [pmid: 14562131].
Rajpurkar A, Dhabuwala CB. Comparison of satisfaction rates and erectile function in patients treated with sildenafil, intracavernous prostaglandin E1 and penile implant surgery for erectile dysfunction in urology practice. Br J Urol. 2003;170(1):159-163.
Rakic Z, Starcevic V, Starcevic VP, et al. Testosterone treatment in men with erectile disorder and low levels of total testosterone in serum. Arch Sex Behav. 1997;26(5):495-504. [pmid: 9343635].
Ralph DJ, Sleep DJ, Perdok RJ, et al. Adverse events and patient tolerability of apomorphine SL 2 and 3 mg: A cross-study analysis of phase II and III studies. European Urology Supplements. 2002;1(3):21-27.
Ramasubbu Rajamannar. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Rashid A. The efficacy and safety of PDE5 inhibitors. [Review] [30 refs]. Clin Cornerstone. 2005;7(1):47-56. [pmid: 16156423].
Reiter WJ, Schatzl G, Mark I, et al. Dehydroepiandrosterone in the treatment of erectile dysfunction in patients with different organic etiologies. Urol Res. 2001;29(4):278-281. [pmid: 11585284].
Reznik I, Zemishlany Z, Kotler M, et al. Sildenafil citrate for the sexual dysfunction in antidepressant-treated male patients with posttraumatic stress disorder. A preliminary pilot open-label study. Psychotherapy & Psychosomatics. 2002;71(3):173-176. [pmid: 12021561].
Richardson JD. Intracorporeal injections for the treatment of impotence. Med J Aust. 1991;155(10):688. [pmid: 1943899].
Richter S, Vardi Y, Ringel A, et al. Intracavernous injections: still the gold standard for treatment of erectile dysfunction in elderly men. Int J Impot Res. 2001;13(3):172-175. [pmid: 11525316].
Rizvi K, Hampson JP, Harvey JN. Do lipid-lowering drugs cause erectile dysfunction? A systematic review.[see comment]. [Review] [35 refs]. Fam Pract. 2002;19(1):95-98. [pmid: 11818357].
Roach M, Winter K, Michalski JM, et al. Penile bulb dose and impotence after three-dimensional conformal radiotherapy for prostate cancer on RTOG 9406: findings from a prospective, multi-institutional, phase I/II dose-escalation study. Int J Radiat Oncol Biol Phys. 2004;60(5):1351-1356. [pmid: 15590164].
Robinson PK. An observational study of prostaglandin E-1: comparing trial and maintenance dose. Urol Nurs. 1994;14(3):76-78. [pmid: 7732420].
Rodilla F, Fuentes MD, Chuan P, et al. Penile self-injection for impotence in patients after radical cystectomy. Journal of Clinical Pharmacy & Therapeutics. 1994;19(6):359-360. [pmid: 7876367].
Rodrigues M, Granegger S, O'Grady J, et al. Accumulation of platelets as a key mechanism of human erection. A scintigraphic study in patients with erectile dysfunction receiving intracavernous injection of PGE1, papaverine/phentolamine. Advances in Experimental Medicine & Biology. 1997;43:379-82.
Rodrigues M, O'Grady J, Stackl W, et al. Accumulation of platelets as a key mechanism of human erection. Thromb Res. 1998;91(2):53-56. [pmid: 9722020].
Rodriguez Vela L, Lledo Garcia E, Rajmil O, et al. [Tadalafil vs sildenafil patient preference in Spanish men with erectile dysfunction: results from an International Multicentric Study]. Actas Urol Esp. 2006;30(1):67-79. [pmid: 16703733].
Rosas SE, Wasserstein A, Kobrin S, et al. Preliminary observations of sildenafil treatment for erectile dysfunction in dialysis patients. Am J Kidney Dis. 2001;37(1):134-137. [pmid: 11136178].
Rosas-Vargas H, Coral-Vazquez RM, Tapia R, et al. Glu298Asp endothelial nitric oxide synthase polymorphism is a risk factor for erectile dysfunction in the Mexican Mestizo population. J Androl. 2004;25(5):728-732. [pmid: 15292102].
Rosen RC, Shabsigh R, Kuritzky L, et al. The efficacy of tadalafil in improving sexual satisfaction and overall satisfaction in men with mild, moderate, and severe erectile dysfunction: A retrospective pooled analysis of data from randomized, placebo-controlled clinical trials. Current Medical Research & Opinion. 2005;21(11):1701-1709. [pmid: 16307689].
Rosen R, Janssen E, Wiegel M, et al. Psychological and interpersonal correlates in men with erectile dysfunction and their partners: a pilot study of treatment outcome with sildenafil. J Sex Marital Ther. 2006;32(3):215-234. [pmid: 16809250].
Rosenstock HA, Axelrad SD. Erectile dysfunction: on the efficacy of a phosphodiesterase inhibitor with concurrent sex therapy. Asian J Androl. 1999;1(4):207-210. [pmid: 11225896].
Rowland DL, Boedhoe HSM, Dohle G, et al. Intracavernosal self-injection therapy in men with erectile dysfunction: Satisfaction and attrition in 119 patients. Int J Impot Res. 1999;11(3):145-151. [pmid: 10404283].
Rowland DL, Myers L, Culver A, et al. Bupropion and sexual function: a placebo-controlled prospective study on diabetic men with erectile dysfunction. J Clin Psychopharmacol. 1997;17(5):350-357. [pmid: 9315985].
Rubio-Aurioles E, Porst H, Eardley I, et al. Comparing vardenafil and sildenafil in the treatment of men with erectile dysfunction and risk factors for cardiovascular disease: a randomized, double-blind, pooled crossover study. Br J Sex Med. 2006;3(6):1037-1049.
Rudkin L, Taylor M J, Hawton K. Strategies for managing sexual dysfunction induced by antidepressant medication. [Review][61 refs]. Cochrane Database Syst Rev 2004;(4):CD003382
Ruof J, Graf-Morgenstern M, Mnller MJ. Quality of life in patients with erection difficulties: Evaluation of a German version of the “Quality of life measure for men with erection difficulties” (QoL-Med). Aktuel Urol. 2001;32(1):21-26.
Saad F, Grahl AS, Aversa A, et al. Effects of testosterone on erectile function: implications for the therapy of erectile dysfunction. BJU Int. 2007;99(5):988-992. [pmid: 17309554].
Saad F, Hoesl CE, Oettel M, et al. Dehydroepiandrosterone treatment in the aging male - What should the urologist know?. Eur Urol. 2005;48(5):724-733. [pmid: 16137821].
Sadeghi-Nejad H, Lim H, Long K, et al. Assessment of the efficacy of Viagra (sildenafil citrate) using the Erectile Dysfunction Inventory of Treatment Satisfaction (EDITS). Urol Int. 2003;71(1):100-102. [pmid: 12845271].
Sadovsky R, Althof S. Men's sexual issues. Clinics in Family Practice. 2004;6(4 SPEC.ISS.):863-915.
Sahu MA, Ayyaz M, Chaudhry Z. Intracavernous injections of papaverine and phentolamine for treatment of impotence. J Coll Physicians Surg Pak. 1997;7(3):102-104.
Saie DJ, Sills ES. Hyperprolactinemia presenting with encephalomalacia-associated seizure disorder and infertility: A novel application for bromocriptine therapy in reproductive endocrinology. Neuroendocrinol Lett. 2005;26(5):533-537. [pmid: 16264405].
Salama N. Nocturnal electrobioimpedance volumetric assessment in diabetic men with erectile dysfunction before and after tadalafil intake. Int J Impot Res. 2004;16(5):441-447. [pmid: 15057255].
Salonia A, Rigatti P, Montorsi F. Sildenafil in erectile dysfunction: a critical review. Curr.Med Res Opin. 2003;19(4):241-262. [pmid: 12841917].
Salonia Andrea, Briganti Alberto, Montorsi Piero, et al. Safety and tolerability of oral erectile dysfunction treatments in the elderly. [References]. Drugs and Aging. 2005;22(4):323-338. [pmid: 15839721].
Sato Y, Horita H, Adachi H, et al. Effect of oral administration of prostaglandin E1 on erectile dysfunction. Br J Urol. 1997;80(5):772-775. [pmid: 9393301].
Savoca G, Silvestre G, Belgrano E. Intracavernosal injection therapy and surgical therapy in diabetic patients with erectile dysfunction. [Review] [26 refs]. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):53-57.
Schanz S, Hauswirth U, Ulmer A, et al. Prostaglandin E(1) ethyl ester, a new agent for topical penile therapy. Int J Impot Res. 2002;14(4):317-318. [pmid: 12152124].
Schimmer AD, Ali V, Stewart AK, et al. Male sexual function after autologous blood or marrow transplantation. Biology of Blood & Marrow Transplantation. 2001;7(5):279-283. [pmid: 11400950].
Schmid DM, Schurch B, Hauri D. Sildenafil in the treatment of sexual dysfunction in spinal cord-injured male patients. Eur Urol. 2000;38(2):184-193. [pmid: 10895011].
Schouman M, Lacroix P, Amer M. Suppression of prostaglandin E1-induced pain by dilution of the drug with lidocaine before intracavernous injection. Br J Urol. 1992;148(4):1266.
Schroder FH, Whelan P, De Reijke TM, et al. Metastatic prostate cancer treated by flutamide versus cyproterone acetate. Final analysis of the “European Organization for Research and Treatment of Cancer” (EORTC) Protocol 30892. Eur Urol. 2004;45(4):457-464. [pmid: 15041109].
Schulman CC, Shen W, Stothard DR, et al. Integrated analysis examining first-dose success, success by dose, and maintenance of success among men taking tadalafil for erectile dysfunction. Urology. 2004;64(4):783-788. [pmid: 15491720].
Schultheiss D, Stief CG. Physiology and pathophysiology of erection: Consequences for present medical therapy of erectile dysfunction. Andrologia. 1999;31(SUPPL. 1):59-64. [pmid: 10643521].
Schultheiss D, Hiltl DM, Meschi MR, et al. Pilot study of the transdermal application of testosterone gel to the penile skin for the treatment of hypogonadotropic men with erectile dysfunction. World J Urol. 2000;18(6):431-435. [pmid: 11204264].
Seftel AD. From aspiration to achievement: Assessment and noninvasive treatment of erectile dysfunction in aging men. J Am Geriatr Soc. 2005;53(1):119-130. [pmid: 15667388].
Segraves RT, Lee J, Stevenson R, et al. Tadalafil for treatment of erectile dysfunction in men on antidepressants. J Clin Psychopharmacol. 2007;27(1):62-66. [pmid: 17224715].
Seidman SN, Pesce VC, Roose SP. High-dose sildenafil citrate for selective serotonin reuptake inhibitor-associated ejaculatory delay: open clinical trial. Hillside J Clin Psychiatry. 2003;64(6):721-725.
Setter SM, Iltz JL, Fincham JE, et al. Phosphodiesterase 5 inhibitors for erectile dysfunction. [Review] [75 refs]. Ann Pharmacother. 2005;39(78):1286-1295. [pmid: 15941818].
Sexton WJ, Benedict JF, Jarow JP. Comparison of long-term outcomes of penile prostheses and intracavernosal injection therapy.[see comment]. Br J Urol. 1998;159(3):811-815.
Shabbir M, Mikhailidis DM, Morgan RJ. Erectile dysfunction: an underdiagnosed condition associated with multiple risk factors.[comment]. Current Medical Research & Opinion. 2004;20(5):603-606. [pmid: 15140326].
Shabsigh R. Testosterone therapy in erectile dysfunction and hypogonadism. Br J Sex Med. 2005;2(6):785-792.
Shabsigh R. Hypogonadism and erectile dysfunction: The role for testosterone therapy. Int J Impot Res. 2003;15(SUPPL. 4):S9-S13. [pmid: 12934045].
Shabsigh R, Burnett AL, Eardley I, et al. Time from dosing to sexual intercourse attempts in men taking tadalafil in clinical trials. BJU Int. 2005;96(6):857-863. [pmid: 16153217].
Shabsigh R, Katz M, Yan G, et al. Cardiovascular issues in hypogonadism and testosterone therapy. [Review] [44 refs]. Am J Cardiol. 2005;96(12B):67M-72M. [pmid: 15979436].
Shabsigh R, Padma-Nathan H, Gittleman M, et al. Intracavernous alprostadil alfadex (EDEX/VIRIDAL) is effective and safe in patients with erectile dysfunction after failing sildenafil (Viagra). Urology. 2000;55(4):477-480. [pmid: 10736486].
Shamloul R. Management of honeymoon impotence. Br J Sex Med. 2006;3(2):361-366.
Shamloul R, Atteya A, Elnashaar A, et al. Intracavernous sodium nitroprusside (SNP) versus papaverine/phentolamine in erectile dysfunction: A comparative study of short- term efficacy and side- effects. Br J Sex Med. 2005;2(1):117-120.
Shamloul Rany, Kamel Ihab, et al. Early Treatment of Cavernositis Resulted in Erectile Function Preservation. [References]. Br J Sex Med. 2006;3(2):320-322.
Sharlip ID. Editorial comment. International Braz J Urol. 2005;31(4):354-355.
Sharlip ID. Can self-injection therapy cure impotence?. [Review] [7 refs]. Advances in Experimental Medicine & Biology. 1997;43:383-86.
Sharma RK, Prasad N, Kapoor R, et al. Treatment of erectile dysfunction with sidenafil citrate in renal transplant recipient: a cross over placebo controlled trial [abstract]. Indian Journal of Nephrology. 2002;12(4):23-238.
Shemtov OM, Radomski SB, Crook J. Success of sildenafil for erectile dysfunction in men treated with brachytherapy or external beam radiation for prostate cancer. Can J Urol. 2004;11(6):2450-2455. [pmid: 15636671].
Shenfeld OZ, Gofrit ON, Gdor Y, et al. The role of sildenafil in the treatment of erectile dysfunction in patients with pelvic fracture urethral disruption. Br J Urol. 2004;172(6 I):2350-2352.
Sheu JY, Chen KK, Lin AT, et al. Long-term efficacy and safety of sildenafil for patients with erectile dysfunction. Journal of the Chinese Medical Association: JCMA. 2003;66(8):480-486. [pmid: 14604312].
Shigemura K, Arakawa S, Kamidono S, et al. Effect of sildenafil on arterial stiffness, as assessed by pulse wave velocity, in patients with erectile dysfunction. Int J Urol. 2006;13(7):956-959. [pmid: 16882062].
Shimon I, Lubina A, Gorfine M, et al. Feedback inhibition of gonadotropins by testosterone in men with hypogonadotropic hypogonadism: comparison to the intact pituitary-testicular axis in primary hypogonadism. J Androl. 2006;27(3):358-364. [pmid: 16474013].
Shokeir AA, Alserafi MA, Mutabagani H. Intracavernosal versus intraurethral alprostadil: a prospective randomized study. BJU Int. 1999;83(7):812-815. [pmid: 10368203].
Siegel RL, Dubin NH, Andrade JR. Sildenafil citrate and sperm function [3] (multiple letters). American Journal of Obstetrics & Gynecology. 2001;184(4):777-778. [pmid: 11262489].
Sighinolfi MC, de Stefani S, Mofferdin A, et al. Intracavernous prostaglandin E1 infusion in diabetes with associated ischemic necrosis of the glans penis. Br J Urol. 2004;171(6 I):2380.
Silvestri A, Galetta P, Cerquetani E, et al. Report of erectile dysfunction after therapy with beta-blockers is related to patient knowledge of side effects and is reversed by placebo.[see comment]. Eur Heart J. 2003;24(21):1928-1932. [pmid: 14585251].
Singh AN, Scurlock H, Catalan J. Paroxetine induced erectile dysfunction successfully treated with yohimbine in patients suffering from HIV infection. Journal of Serotonin Research. 1995;1(4):283-285.
Slob AK, Verhulst ACM, Gijs L, et al. Intracavernous injection during diagnostic screening for erectile dysfunction: Five-year experience with over 600 patients. [References]. Br J Sex Med. 2002;28(1):61-70.
Smith KM, Romanelli F. Recreational use and misuse of phosphodiesterase 5 inhibitors. [Review] [56 refs]. Journal of the American Pharmacists Association: JAPhA. 2005;45(1):63-72. [pmid: 15730119].
Soh J, Naya Y, Ushijima S, et al. Efficacy of sildenafil for Japanese patients with audio-visual sexual stimulation (AVSS) test by the RigiScan Plus. Arch Androl. 2006;52(3):163-168. [pmid: 16574596].
Soler JM, Previnaire JG, Denys P, et al. Phosphodiesterase inhibitors in the treatment of erectile dysfunction in spinal cord-injured men. Proc Annu Clin Spinal Cord Inj Conf. 2007;45(2):169-173.
Sommer F, Engelmann U. Vardenafil: Bayer Yakuhin. Curr Opin Investig Drugs. 2002;3(4):607-613.
Sonksen J, Biering-Sorensen F. Transcutaneous nitroglycerin in the treatment of erectile dysfunction in spinal cord injured. Paraplegia. 1992;30(8):554-557. [pmid: 1522996].
Sparwasser C, Treiber U, Bahren W, et al. Postoperative erectile dysfunction; evaluation and treatment with intracavernous vasoactive injections. Progress in Clinical & Biological Research. 1991;370:349-354. [pmid: 1924468].
Speckens AE, Kattemolle MR, Hengeveld MW, et al. A prospective long-term follow-up study of patients evaluated for erectile dysfunction: outcome and associated factors. Int J Impot Res. 1995;7(2):101-110. [pmid: 7496438].
Speel TGW, Bleumer I, Diemont WL, et al. The value of sildenafil as mode of stimulation in pharmaco-penile duplex ultrasonography. Int J Impot Res. 2001;13(4):189-191. [pmid: 11494073].
Sperling H, Eisenhardt A, Virchow S, et al. Sildenafil response is influenced by the G protein beta 3 subunit GNB3 C825T polymorphism: a pilot study. Br J Urol. 2003;169(3):1048-1051.
Stanislavov R, Nikolova V. Treatment of erectile dysfunction with pycnogenol and L-arginine. J Sex Marital Ther. 2003;29(3):207-213. [pmid: 12851125].
Steers W, Guay AT, Leriche A, et al. Assessment of the efficacy and safety of Viagra (sildenafil citrate) in men with erectile dysfunction during long-term treatment. Int J Impot Res. 2001;13(5):261-267. [pmid: 11890512].
Steidle CP, McCullough AR, Kaminetsky JC, et al. Early sildenafil dose optimization and personalized instruction improves the frequency, flexibility, and success of sexual intercourse in men with erectile dysfunction. Int J Impot Res. 2007;19(2):154-160. [pmid: 16858367].
Stephenson RA, Mori M, Hsieh YC, et al. Treatment of erectile dysfunction following therapy for clinically localized prostate cancer: patient reported use and outcomes from the Surveillance, Epidemiology, and End Results Prostate Cancer Outcomes Study. Br J Urol. 2005;174(2):646-650.
Stief CG, Holmquist F, Djamilian M, et al. Preliminary results with the nitric oxide donor linsidomine chlorhydrate in the treatment of human erectile dysfunction. Br J Urol. 1992;148(5):1437-1440.
Stief CG, Uckert S, Jonas U. Strategies in the oral pharmacotherapy of male erectile dysfunction viewed from bench and bedside (Part II). The Journal of Mens Health & Gender. 2005;2(3):325-332.
Stief CG, Wetterauer U, Schaebsdau FH, et al. Calcitonin-gene-related peptide: a possible role in human penile erection and its therapeutic application in impotent patients. Br J Urol. 1991;146(4):1010-1014.
Stief C, Padley RJ, Perdok RJ, et al. Cross-study review of the clinical efficacy of apomorphine SL 2 and 3 mg: Pooled data from three placebo-controlled, fixed-dose crossover studies. European Urology Supplements. 2002;1(3):12-20.
Strahilevitz J, Rahav G, Schroers HJ, et al. An outbreak of Phialemonium infective endocarditis linked to intracavernous penile injections for the treatment of impotence. Clin Infect Dis. 2005;40(6):781-786. [pmid: 15736008].
Stroberg P, Murphy A, Costigan T. Switching patients with erectile dysfunction from sildenafil citrate to tadalafil: results of a European multicenter, open-label study of patient preference. Clin Ther. 2003;25(11):2724-2737. [pmid: 14693300].
Stuckey BGA. Tadalafil phase 3 experience. European Urology Supplements. 2002;1(8):25-30.
Swartz DA, Todd MW. Intracavernous papaverine and glaucoma.[see comment]. JAMA. 1990;264(5):570. [pmid: 2366292].
Tam PY, Keller T, Poppiti R, et al. Hemodynamic effects of transurethral alprostadil measured by color duplex ultrasonography in men with erectile dysfunction. Br J Urol. 1998;160(4):1321-1324.
Tam SW, Worcel M, Wyllie M. Yohimbine: a clinical review. [Review] [152 refs]. Pharmacol Ther. 2001;91(3):215-243. [pmid: 11744068].
Tanaka T. Papaverine hydrochloride in peripheral blood and the degree of penile erection. Br J Urol. 1990;143(6):1135-1137.
Tariq SH, Haleem U, Omran ML, et al. Erectile dysfunction: Etiology and treatment in young and old patients. Clin Geriatr Med. 2003;19(3):539-551. [pmid: 14567006].
Tas A, Ersoy A, Ersoy C, et al. Efficacy of sildenafil in male dialysis patients with erectile dysfunction unresponsive to erythropoietin and/or testosterone treatments. Int J Impot Res. 2006;18(1):61-68. [pmid: 16177828].
Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005;88(3):241-254. [pmid: 16162361].
Tekdogan U, Tuncel A, Tuglu D, et al. Effect of sildenafil citrate treatment on serum dehydroepiandrosterone sulfate levels in patients with erectile dysfunction. Urology. 2006;68(3):626-630. [pmid: 16979704].
Telias Isaac Darwin, Kadmon-Telias Ana, et al. Four cases of erectile dysfunction in substance abusers treated with sildenafil. [References]. J Addict Dis. 2002;97(11):1473-1474.
Teloken C, Rhoden EL, Sogari P, et al. Therapeutic effects of high dose yohimbine hydrochloride on organic erectile dysfunction. Br J Urol. 1998;159(1):122-124.
Terradas C, Levalle O, Nagelberg A, et al. Sildenafil improves nocturnal penile erections in organic impotence. Int J Impot Res. 2001;13(2):125-129. [pmid: 11426352].
Tomlinson John M, Wright David, E-Mail Address et al. Impact of erectile dysfunction and its subsequent treatment with sildenafil: Qualitative study. [References]. BMJ: British Medical Journal 2004;328(7447):No
Tomsak R. PDE5 inhibitors and permanent visual loss. Int J Impot Res. 2005;17(6):547-549. [pmid: 16193072].
Tosti A, Pazzaglia M, Soli M, et al. Evaluation of sexual function with an international index of erectile function in subjects taking finasteride for androgenetic alopecia.[see comment]. Arch Dermatol. 2004;140(7):857-858. [pmid: 15262698].
Trinchieri A, Nicola M, Masini F, et al. Prospective comprehensive assessment of sexual function after retropubic non nerve sparing radical prostatectomy for localized prostate cancer. Arch Ital Urol Androl. 2005;77(4):219-223. [pmid: 16444937].
Truss MC, Becker AJ, Thon WF, et al. Intracavernous calcitonin gene-related peptide plus prostaglandin E1: possible alternative to penile implants in selected patients. Eur Urol. 1994;26(1):40-45. [pmid: 7925528].
Tsai YS, Lin JS, Lin YM. Safety and efficacy of alprostadil sterile powder (S. Po., CAVERJECT) in diabetic patients with erectile dysfunction. Eur Urol. 2000;38(2):177-183. [pmid: 10895010].
Tsujimura A, Yamanaka M, Takahashi T, et al. The clinical studies of sildenafil for the ageing male. Int J Androl. 2002;25(1):28-33. [pmid: 11869374].
Turk S, Karalezli G, Tonbul HZ, et al. Erectile dysfunction and the effects of sildenafil treatment in patients on haemodialysis and continuous ambulatory peritoneal dialysis. Nephrol. Dial. Transplant. 2001;16(9):1818-1822. [pmid: 11522864].
Turner LA, Althof SE. The clinical effectiveness of self-injection and external vacuum devices in the treatment of erectile dysfunction: a six-month comparison. Psychiatr Med. 1992;10(2):283-293. [pmid: 1377397].
Turner LA, Althof SE, Levine SB, et al. Twelve-month comparison of two treatments for erectile dysfunction: self-injection versus external vacuum devices. Urology. 1992;39(2):139-144. [pmid: 1736506].
Urciuoli R, Cantisani T A, CarliniI M et al. Prostaglandin E1 for treatment of erectile dysfunction. Cochrane Database Syst Rev 2004;(2):CD001784
Valicenti RK, Choi E, Chen C, et al. Sildenafil citrate effectively reverses sexual dysfunction induced by three-dimensional conformal radiation therapy. Urology. 2001;57(4):769-773. [pmid: 11306401].
Valiquette L, Montorsi F, Hellstrom WJ, et al. Penetration and maintenance of erection with vardenafil: a time-from-dosing analysis. Can J Urol. 2005;12(3):2687-2698. [pmid: 16011816].
van Basten JP, Van Driel MF, Jonker-Pool G, et al. Sexual functioning in testosterone-supplemented patients treated for bilateral testicular cancer. Br J Urol. 1997;79(3):461-467. [pmid: 9117232].
van Moorselaar RJ, Hartung R, Emberton M, et al. Alfuzosin 10 mg once daily improves sexual function in men with lower urinary tract symptoms and concomitant sexual dysfunction. BJU Int. 2005;95(4):603-608. [pmid: 15705088].
Van Ahlen H, Peskar BA, Sticht G, et al. Pharmacokinetics of vasoactive substances administered into the human corpus cavernosum. Br J Urol. 1994;151(5):1227-1230.
Van Dijk M, Skrekas T, De La, et al. The association between lower urinary tract symptoms and sexual dysfunction: Fact or fiction?. Curr Opin Urol. 2005;15(1):39-44. [pmid: 15586029].
Vardi M, Nini A. Phosphodiesterase inhibitors for erectile dysfunction in patients with diabetes mellitus. [Review][49 refs]. Cochrane Database Syst Rev 2007;(1):CD002187
Vardi Y, Sprecher E, Gruenwald I. Logistic regression and survival analysis of 450 impotent patients treated with injection therapy: long-term dropout parameters. Br J Urol. 2000;163(2):467-470.
Vickers MA, De Nobrega AM, Dluhy RG. Diagnosis and treatment of psychogenic erectile dysfunction in a urological setting: Outcomes of 18 consecutive patients. Br J Urol. 1993;149(5 SUPPL.):1258-1261.
Virag R. Indications and early results of sildenafil (Viagra) in erectile dysfunction. Urology. 1999;54(6):1073-1077. [pmid: 10604711].
Virag R. Intracavernous injection of papaverine for erectile failure. 1982. Br J Urol. 2002;167(2 Pt 2):1196.
Virag R, Floresco J, Richard C. Impairment of shear-stress-mediated vasodilation of cavernous arteries in erectile dysfunction. Int J Impot Res. 2004;16(1):39-42. [pmid: 14963469].
Vitezic D. A risk-benefit assessment of sildenafil in the treatment of erectile dysfunction. [Review] [72 refs]. Drug Saf. 2001;24(4):255-265. [pmid: 11330655].
von Heyden B, Donatucci CF, Kaula N, et al. Intracavernous pharmacotherapy for impotence: selection of appropriate agent and dose. [Review] [23 refs]. Br J Urol. 1993;149(5 Pt 2):1288-1290.
Wagner G, Montorsi F, Auerbach S, et al. Sildenafil citrate (VIAGRA) improves erectile function in elderly patients with erectile dysfunction: a subgroup analysis. J Gerontol A Biol.Sci Med Sci. 2001;56(2):M113-M119. [pmid: 11213274].
Wagrell L, Schelin S, Nordling J, et al. Three-year follow-up of feedback microwave thermotherapy versus TURP for clinical BPH: a prospective randomized multicenter study. Urology. 2004;64(4):698-702. [pmid: 15491704].
Wang CJ, Wu CC, Huang CH, et al. A comparative study with intracavernous injection of prostaglandin E1 versus papaverine for the diagnostic assessment of erectile impotence. Gaoxiong Yi Xue Ke Xue Za Zhi. 1992;8(11):585-590. [pmid: 1296038].
Wang ZL, Shao SX, Li B, et al. Sildenafil versus prostaglandin E1 in the management of erectile dysfunction. Journal of Clinical Urology. 2002;17(7):347-349.
Webb DJ, Freestone S, Allen MJ, et al. Sildenafil citrate and blood-pressure-lowering drugs: results of drug interaction studies with an organic nitrate and a calcium antagonist. Am J Cardiol. 1999;83(5A):21C-28C. [pmid: 10073779].
Weber DC, Bieri S, Kurtz JM, et al. Prospective pilot study of sildenafil for treatment of postradiotherapy erectile dysfunction in patients with prostate cancer. Am J Clin Oncol. 1999;17(11):3444-3449.
Weidner W, Schroeder-Printzen I, Fischer C, et al. Experience in the treatment of erectile dysfunction using the intracavernosal self-injection of papaverine: Results of a prospective study after a median follow-up of 42 months involving 135 patients and 10766 injections. World J Urol. 1992;10(3):179-182.
Weiss JN, Badlani GH, Ravalli R, et al. Reasons for high drop-out rate with self-injection therapy for impotence. Int J Impot Res. 1994;6(3):171-174. [pmid: 7735362].
Weiss JN, Ravalli R, Badlani GH. Intracavernous pharmacotherapy in psychogenic impotence. Urology. 1991;37(5):441-443. [pmid: 1708925].
Wen HS, Hsieh CH, Hsu GL, et al. The synergism of penile venous surgery and oral sildenafil in treating patients with erectile dysfunction.[see comment]. Int J Androl. 2005;28(5):297-303. [pmid: 16128990].
Werneke U, Crowe M. Review of patients with erectile dysfunction attending the Maudsley psychosexual clinic in 1999: The impact of sildenafil. Sexual & Relationship Therapy. 2002;17(2):171-185.
Werthman P, Rajfer J. MUSE therapy: preliminary clinical observations. Urology. 1997;50(5):809-811. [pmid: 9372900].
Wespes E, Rammal A, Garbar C. Sildenafil non-responders: haemodynamic and morphometric studies. Eur Urol. 2005;48(1):136-139. [pmid: 15967263].
Williams G. Male erectile dysfunction. Prescribers' Journal. 2000;40(1):49-58.
Williams G, Abbou CC, Amar ET, et al. The effect of transurethral alprostadil on the quality of life of men with erectile dysfunction, and their partners. MUSE Study Group. Br J Urol. 1998;82(6):847-854. [pmid: 9883223].
Williams T, Honeywell M, Branch E et al. Tadalafil in the treatment of erectile dysfunction. P & T 2004;29(5):
Willke RJ, Glick HA, McCarron TJ, et al. Quality of life effects of alprostadil therapy for erectile dysfunction. Br J Urol. 1997;157(6):2124-2128.
Wise Thomas N. Psychosocial side effects of sildenafil therapy for erectile dysfunction. J Sex Marital Ther. 1999;25(2):145-150. [pmid: 10327384].
Wolfson B, Pickett S, Scott NE, et al. Intraurethral prostaglandin E-2 cream: a possible alternative treatment for erectile dysfunction. Urology. 1993;42(1):73-75. [pmid: 8328127].
Wood P L. Slow, tedious but essential: The need for incremental R&D. Current Drug Discovery 2004;(pp 31–35):-35.
Wu CC, Xue ZY, Apichat K, et al. The use of alprostadil sterile powder in a home self-injection study of Asian men with erectile dysfunction. Clin Ther. 1996;18(2):256-264. [pmid: 8733986].
Wylie Kevan R, Hallam-Jones Ruth A, Steward David, et al. The combination of penoscrotal rings and PDE5i's in the treatment of erectile dysfunction - the Sheffield PDE5i and Ring Duo Technique. Two case reports. [References]. Sexual and Relationship Therapy. 2006;21(2):209-215.
Yaman O, Akand M, Gursoy A, et al. The effect of diabetes mellitus treatment and good glycemic control on the erectile function in men with diabetes mellitus-induced erectile dysfunction: a pilot study. Br J Sex Med. 2006;3(2):344-348.
Yaman O, Tokatli Z, Akand M, et al. Characteristics of sildenafil erections in healthy young men. Asian J Androl. 2005;7(4):395-398. [pmid: 16281087].
Yassin AA, Saad F. Improvement of sexual function in men with late-onset hypogonadism treated with testosterone only. Br J Sex Med. 2007;4(2):497-501.
Yassin AA, Saad F. Dramatic improvement of penile venous leakage upon testosterone administration. A case report and review of literature. Andrologia. 2006;38(1):34-37. [pmid: 16420241].
Yassin AA, Saad F, Traish A. Testosterone undecanoate restores erectile function in a subset of patients with venous leakage: a series of case reports. Br J Sex Med. 2006;3(4):727-735.
Yenicerioglu Y, Kefi A, Aslan G, et al. Efficacy and safety of sildenafil for treating erectile dysfunction in patients on dialysis. BJU Int. 2002;90(4):442-445. [pmid: 12175405].
Zaher TF. Papaverine plus prostaglandin E1 versus prostaglandin E1 alone for intracorporeal injection therapy. Int Urol Nephrol. 1998;30(2):193-196. [pmid: 9607891].
Zargooshi J. Unconsummated marriage: clarification of aetiology; treatment with intracorporeal injection. BJU Int. 2000;86(1):75-79. [pmid: 10886087].
Zasler ND. Therapeutic approaches to sexual impotence. Hospital Practice (Office Edition). 1988;23(7):197-200.
Zelefsky MJ, McKee AB, Lee H, et al. Efficacy of oral sildenafil in patients with erectile dysfunction after radiotherapy for carcinoma of the prostate. Urology. 1999;53(4):775-778. [pmid: 10197855].
Zesiewicz TA, Helal M, Hauser RA. Sildenafil citrate (Viagra) for the treatment of erectile dysfunction in men with Parkinson's disease. Mov Disord. 2000;15(2):305-308. [pmid: 10752581].
Zhang Y, Guan DL, Ou TW, et al. Sildenafil citrate treatment for erectile dysfunction after kidney transplantation. Transplant Proc. 2005;37(5):2100-2103. [pmid: 15964350].
Ziegler D. Management of erectile dysfunction in diabetic patients. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):58-65.
Zippe CD, Kedia AW, Kedia K, et al. Treatment of erectile dysfunction after radical prostatectomy with sildenafil citrate (Viagra). Urology. 1998;52(6):963-966. [pmid: 9836537].
Zippe CD, Kedia S, Kedia AW, et al. Sildenafil citrate (Viagra) after radical retropubic prostatectomy: pro. Urology. 1999;54(4):583-586. [pmid: 10510910].
Zlotta AR, Teillac P, Raynaud JP, et al. Evaluation of male sexual function in patients with Lower Urinary Tract Symptoms (LUTS) associated with Benign Prostatic Hyperplasia (BPH) treated with a phytotherapeutic agent (Permixon), Tamsulosin or Finasteride. Eur Urol. 2005;48(2):269-276. [pmid: 15939527].
Zorgniotti A. ‘“On demand” oral drug for erection in impotent men’. Br J Urol 1992;147308
Zorgniotti AW. Experience with buccal phentolamine mesylate for impotence. Int J Impot Res. 1994;6(1):37-41. [pmid: 7517275].
Zusman RM, Morales A, Glasser DB, et al. Overall cardiovascular profile of sildenafil citrate. [Review] [33 refs]. Am J Cardiol. 1999;83(5A):35C-44C.

## Not applicable

Annual update 2004/2005 - Treatment of genitourinary disorders. Drugs of the Future 2005;30(9):931–934.
Abrams J. Time course of the interaction between tadalafil and nitrates.[comment]. J Am Coll Cardiol. 2004;43(11):2150-2151. [pmid: 15172433].
Adaikan PG, Chong YS, Chew SSL, et al. Male sexual dysfunction. Curr Obstet Gynaecol. 2000;10(1):23-28.
Ahl J, Kinon B J, Liu-Seifert H. Sexual dysfunction associated with neuroleptic-induced hyperprolactinemia improves with reduction in prolactin levels. Ann N Y Acad Sci 2004;1032(pp 289–290):-290.
Ahuja SK, Krane NK, Hellstrom WJ. Penile prostheses in the management of impotence in patients with end-stage renal disease. J La State Med Soc. 1998;150(1):32-34. [pmid: 9448384].
Akbari F, Alavi M, Esteghamati A, et al. Effect of renal transplantation on sperm quality and sex hormone levels. BJU Int. 2003;92(3):281-283. [pmid: 12887484].
Akkus E, Kadioglu A, Esen A, et al. Prevalence and correlates of erectile dysfunction in Turkey: a population-based study. Eur Urol. 2002;41(3):298-304. [pmid: 12180232].
Alexandre B, Lemaire A, Desvaux P, et al. Intracavernous injections of prostaglandin E1 for erectile dysfunction: patient satisfaction and quality of sex life on long-term treatment. Br J Sex Med. 2007;4(2):426-431.
Alfonso A, Rieniets KI, Vigersky RA. Incidence and clinical significance of elevated macroprolactin levels in patients with hyperprolactinemia. Endocr Pract. 2006;12(3):275-280. [pmid: 16772199].
Alivizatos G, Skolarikos A, Laguna P. Recent data upon impotence, incontinence and quality of life issues concerning radical prostatectomy. [Review] [74 refs]. Arch Esp Urol. 2003;56(3):321-330. [pmid: 12768997].
Althof SE. Quality of life and erectile dysfunction. Urology. 2002;59(6):803-810. [pmid: 12031357].
Althof SE, Corty EW, Levine SB, et al. EDITS: development of questionnaires for evaluating satisfaction with treatments for erectile dysfunction. Urology. 1999;53(4):793-799. [pmid: 10197859].
Althof Stanley E, Turner Louisa A. Self-injection therapy and external vacuum devices in the treatment of erectile dysfunction: Methods and outcome. Rosen, Raymond C (Ed); Leiblum, Sandra Risa (Ed) 1992;(1992):378
Anderson RA, Bancroft J, Wu FC. The effects of exogenous testosterone on sexuality and mood of normal men. Journal of Clinical Endocrinology & Metabolism. 1992;75(6):1503-1507. [pmid: 1464655].
Anderson RA, Martin CW, Kung AW, et al. 7Alpha-methyl-19-nortestosterone maintains sexual behavior and mood in hypogonadal men. Journal of Clinical Endocrinology & Metabolism. 1999;84(10):3556-3562. [pmid: 10522995].
Anderson RA, Wallace AM, Sattar N, et al. Evidence for tissue selectivity of the synthetic androgen 7 alpha-methyl-19-nortestosterone in hypogonadal men. Journal of Clinical Endocrinology & Metabolism. 2003;88(6):2784-2793. [pmid: 12788888].
Andersson KE. Pharmacology of penile erection. Pharmacol Rev. 2001;53(3):417-450. [pmid: 11546836].
Andolsek KM. Alprostadil for the treatment of erectile dysfunction. Am Fam Physician. 1997;55(5):1902-1903.
Andriole G, Bruchovsky N, Chung LWK, et al. Dihydrotestosterone and the prostate: The scientific rationale for 5a-reductase inhibitors in the treatment of benign prostatic hyperplasia. Br J Urol. 2004;172(4 I):1399-1403.
Anonymous. Tadalafil: new preparation. Slightly more convenient, but poorly assessed in organic disorders. Prescrire Int 2003;12(68):213–215.
Anonymous. Tadalafil (cialis) for erectile dysfunction. Medical Letter on Drugs & Therapeutics 2003;45(1172):101–102.
Anonymous. First study of Viagra in black men demonstrates effective, well-tolerated treatment. Urol Nurs 2002;22(4):285–286.
Anonymous. Study shows patients taking vardenafil consistently completed sexual intercourse. Urol Nurs 2001;21(6):413–414.
Anonymous. Apomorphine (TAP holdings). 6a beta-aporphine-10,11-diol hydrochloride hemihydrate, apomorphine hydrochloride, spontane, Uprima. Drugs in R & D 1999;2(6):415–416.
Anonymous. Intraurethral alprostadil for impotence. Medical Letter on Drugs & Therapeutics 1997;39(997):32
Anonymous. Treatment for impotence gains FDA approval. Am J Health Syst Pharm 1995;52(19):2078–2079.
Anonymous. Intracavernous injection of alprostadil for erectile dysfunction. Medical Letter on Drugs & Therapeutics 1995;37(958):83–84.
Anonymous. Vardenafil works for 10 hours. Can Pharm J 2005;275(7360):133
Anonymous. Treatment duration of action is important in ED. Can Pharm J 2004;273(7330):878
Anonymous. Dutaseride. Prescrire Int 2004;13(73):183
Anonymous. Erratum: Efficacy and tolerability of sildenafil in Indian males with erectile dysfunction: A double-blind, randomized, placebo controlled, crossover study (Indian Journal of Pharmacology (2004) vol. 37 (5) (317)). Indian J Pharmacol 2004;36(6):391
Anonymous. Partnership struck between Bayer and Schering. Nat Rev Genet 2004;3(10):819
Anonymous. Erectile dysfunction drugs may reduce fertility but help depression. Can Pharm J 2004;272(7294):439
Anonymous. Sildenafil appears safe and effective for some heart failure patients. Can Pharm J 2004;272(7290):310
Anonymous. What to do when oral treatment fails?. Int J Impot Res 2003;15(SUPPL. 7):S30-S32.
Anonymous. Oral drug treatment of erectile dysfunction. Int J Impot Res 2003;15(SUPPL. 7):S27-S29.
Anonymous. Counselling and increased dose of sildenafil improves response in ED. British Journal of Diabetes & Vascular Disease 2003;3(6):445
Anonymous. Improve erectile function early after prostatectomy. Med Today 2003;4(11):8–9.
Anonymous. Recent FDA approval of new erectile dysfunction drug provides first challenge to sildenafil. Geriatrics and Aging 2003;6(8):11
Anonymous. New PDE 5 inhibitor efficacious for erectile dysfunction in diabetics. Cardiology Review 2003;20(10):
Anonymous. Inhaled apomorphine promising for erectile dysfunction treatment. Can Pharm J 2003;271(7261):170
Anonymous. Transurethral alprostadil. Prescrire Int 2002;11(61):144
Anonymous. IDdb News focus. Current Drug Discovery 2003;(pp 10–13):-13.
Anonymous. Sildenafil effective for sexual dysfunction associated with use of antidepressants. Can Pharm J 2003;270(7231):41
Anonymous. Vardenafil prolongs improved erectile function in diabetics. Cardiology Review 2002;19(10):38–39.
Anonymous. Erectile dysfunction treated effectively with tadalafil. Economics of Neuroscience 2001;3(11):19
Anonymous. New erectile dysfunction drug useful in diabetes. Can Pharm J 2001;267(7173):669
Anonymous. Erectile dysfunction - Alprostadil. Manuf Chem Aerosol News 2001;72(11):21
Anonymous. Erectile dysfunction - Vardenafil. Manuf Chem Aerosol News 2001;72(6):25
Anonymous. FDA approves oral therapy for erectile dysfunction. Am J Health Syst Pharm 1998;55(10):981–984.
Anonymous. Sildenafil Viagra(R) UK-92480: Treatment of erectile dysfunction phosphodiesterase V inhibitor. Drugs of the Future 1998;23(2):242–243.
Anonymous. Intracavernosal alprostadil for erectile dysfunction. Hospital Practice (Office Edition) 1996;31(8):136–137.
Anonymous. Intracavernous alprostadil: Effective therapy for erectile dysfunction. Drugs & Therapy Perspectives 1996;7(6):1–5.
Anonymous. Heart drug with ‘viagra side-effect’. Indian J Med Sci 1999;53(5):236
Anonymous. What to do if Viagra won't do. Harvard Mens Health Watch 2005;9(10):4–8.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: intracavernous injection of prostaglandin E1. JAMA 1991;265(24):3321–3323.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: papaverine and phentolamine. JAMA 1990;264(6):752–754.
Ansong KS, Punwaney RB. An assessment of the clinical relevance of serum testosterone level determination in the evaluation of men with low sexual drive. Br J Urol. 1999;162(3 I):719-721.
Ansong KS, Lewis C, Jenkins P, et al. Epidemiology of erectile dysfunction: a community-based study in rural New York State. Ann Epidemiol. 2000;10(5):293-296. [pmid: 10942877].
Arafa M, Eid H, Shamloul R. Significance of phentolamine redosing during prostaglandin E1 penile color Doppler ultrasonography in diagnosis of vascular erectile dysfunction. Int J Urol. 2007;14(5):476-477. [pmid: 17511742].
Araujo AB, O'Donnell AB, Brambilla DJ, et al. Prevalence and incidence of androgen deficiency in middle-aged and older men: Estimates from the Massachusetts male aging study. Journal of Clinical Endocrinology & Metabolism. 2004;89(12):5920-5926. [pmid: 15579737].
Araujo Andre B, Durante Richard, Feldman Henry A, et al. The relationship between depressive symptoms and male erectile dysfunction: Cross-sectional results from the Massachusetts male aging study. Psychosom Med. 1998;60(4):458-465. [pmid: 9710291].
Arnavaz A, Aurich A, Weissenborn K, et al. Effect of sildenafil (Viagra) on cerebral blood flow velocity: a pilot study. Psychiatry Res. 2003;122(3):207-209. [pmid: 12694895].
Arnold R, Beer D, Bhalay G, et al. 8-Aryl xanthines potent inhibitors of phosphodiesterase 5. Bioorg Med Chem Lett. 2002;12(18):2587-2590. [pmid: 12182866].
Aronson JK. Features of this month's Journal. Br J Clin Pharmacol. 2003;55(4):327-328.
Arslan D, Esen AA, Secil M, et al. A new method for the evaluation of erectile dysfunction: sildenafil plus Doppler ultrasonography. Br J Urol. 2001;166(1):181-184.
Arthur R. Cardiovascular disorders and erectile dysfunction. British Journal of Cardiology. 2002;9(3):144-145.
Ashton AK, Jamerson BD, Weinstein WL, et al. Antidepressant-related adverse effects impacting treatment compliance: Results of a patient survey. Current Therapeutic Research, Clinical & Experimental. 2005;66(2):96-106.
Atala A. What's new in urology. J Am Coll Surg. 2004;199(3):446-461. [pmid: 15325616].
Atikeler MK, Gecit I, Senol FA. Optimum usage of prilocaine-lidocaine cream in premature ejaculation. Andrologia. 2002;34(6):356-359. [pmid: 12472618].
Atmaca M, Kuloglu M, Tezcan E. A new atypical antipsychotic: quetiapine-induced sexual dysfunctions. Int J Impot Res. 2005;17(2):201-203. [pmid: 15284834].
Avasthi A, Basu D, Kulhara P, et al. Psychosexual dysfunction in Indian male patients: Revisited after seven years. Arch Sex Behav. 1994;23(6):685-695. [pmid: 7872862].
Aversa A, Mazzilli F, Rossi T, et al. Effects of sildenafil (Viagra) administration on seminal parameters and post-ejaculatory refractory time in normal males. Hum Reprod. 2000;15(1):131-134. [pmid: 10611201].
Aydin S, Unal D, Erol H, et al. Multicentral clinical evaluation of the aetiology of erectile dysfunction: a survey report. International Urology & Nephrology. 2001;32(4):699-703. [pmid: 11989568].
Ayub W, Fletcher S. End-stage renal disease and erectile dysfunction. Is there any hope?. Nephrology Dialysis Transplantation. 2000;15(10):1525-1528.
Bagatell CJ, Heiman JR, Rivier JE, et al. Effects of endogenous testosterone and estradiol on sexual behavior in normal young men.[erratum appears in J Clin Endocrinol Metab 1994 Jun;78(6):1520]. Journal of Clinical Endocrinology & Metabolism. 1994;78(3):711-716. [pmid: 8126146].
Baggaley MR, Hirst JF, Watson JP. Outcome of patients referred to a psychosexual clinic with erectile failure. Sexual & Marital Therapy. 1996;11(2):123-130.
Bai WJ, Zhu JC, Jiang H, et al. [A comparative study of different vasoactive drugs in the treatment of impotence]. Chinese Journal of Urology. 1992;13(6):453-455.
Bailey J, Evans JP, Hardy M, et al. Synopsis: 2005 Annual Meeting of the American Society of Andrology. J Androl. 2005;26(6):678-688. [pmid: 16291961].
Bancroft J, Munoz M, Beard M, et al. The effects of a new alpha-2 adrenoceptor antagonist on sleep and nocturnal penile tumescence in normal male volunteers and men with erectile dysfunction. Psychosom Med. 1995;57(4):345-356. [pmid: 7480564].
Baniel J, Israilov S, Segenreich E, et al. Comparative evaluation of treatments for erectile dysfunction in patients with prostate cancer after radical retropubic prostatectomy. BJU Int. 2001;88(1):58-62. [pmid: 11446847].
Barnas J, Parker M, Guhring P, et al. The utility of tamsulosin in the management of orgasm-associated pain: a pilot analysis.[see comment]. Eur Urol. 2005;47(3):361-365. [pmid: 15716202].
Barqawi A, O'Donnell C, Kumar R, et al. Correlation between LUTS (AUA-SS) and erectile dysfunction (SHIM) in an age-matched racially diverse male population: data from the Prostate Cancer Awareness Week (PCAW). Int J Impot Res. 2005;17(4):370-374. [pmid: 15889121].
Bartlik Barbara D, Kaplan Peter, Kaplan Helen S. Psychostimulants apparently reverse sexual dysfunction secondary to selective serotonin re-uptake inhibitors. J Sex Marital Ther. 1995;21(4):264-271. [pmid: 8789508].
Bayes M, Rabasseda X, Prous JR. Gateways to Clinical Trials. Methods & Findings in Experimental & Clinical Pharmacology. 2004;26(9):723-753. [pmid: 15632957].
bdel-Khalek M, El-Hammady S, Ibrahiem el. A 4-year follow-up of a randomized prospective study comparing transurethral electrovaporization of the prostate with neodymium: YAG laser therapy for treating benign prostatic hyperplasia. BJU Int. 2003;91(9):801-805. [pmid: 12780836].
Beard S, Hunn A, Wight J. Treatments for spasticity and pain in multiple sclerosis: A systematic review. Health Technol Assess. 2003;7(40):111p.
Beasley CM, Mitchell MI, Dmitrienko AA, et al. The combined use of ibutilide as an active control with intensive electrocardiographic sampling and signal averaging as a sensitive method to assess the effects of tadalafil on the human QT interval.[see comment]. J Am Coll Cardiol. 2005;46(4):678-687. [pmid: 16098435].
Becher E, Glina S. Erectile dysfunction in Latin America and treatment with sildenafil citrate (Viagra): Introduction. Int J Impot Res. 2002;14(SUPPL. 2):S1-S2. [pmid: 12161761].
Bella AJ, Brock GB. Tadalafil: A comprehensive update. Journal of Drug Evaluation. 2004;2(8):225-246.
Benson GS. The clinical evaluation of the patient presenting with erectile dysfunction: what is reasonable?. [Review] [27 refs]. Semin Urol. 1990;8(2):94-99. [pmid: 2191404].
Beretta G, Saltarelli O, Marzotto M, et al. Transcutaneous minoxidil in the treatment of erectile dysfunctions in spinal cord injured men. Acta Eur Fertil. 1993;24(1):27-30. [pmid: 8303971].
Bestane WJ, Bestane MC, Ramos NA. Prospective study of sodium nitroprusside in pharmacologically induced erection. Braz J Urol. 2001;27(2):155-158.
Beutel ME, Wiltink J, Hauck EW, et al. Correlations between hormones, physical, and affective parameters in aging urologic outpatients. Eur Urol. 2005;47(6):749-755. [pmid: 15925068].
Bhatia MS, Malik SC. Dhat syndrome—a useful diagnostic entity in Indian culture. Br J Psychiatry. 1991;159(Nov.):691-695. [pmid: 1756347].
Bivalacqua TJ, Hellstrom WJG. Potential application of gene therapy for the treatment of erectile dysfunction. J Androl. 2001;22(2):183-190. [pmid: 11229791].
Black AM, Day AG, Morales A. The reliability of clinical and biochemical assessment in symptomatic late-onset hypogonadism: Can a case be made for a 3-month therapeutic trial?. BJU Int. 2004;94(7):1066-1070. [pmid: 15541129].
Blander DS, Sanchez-Ortiz RF, Broderick GA. Sex inventories: can questionnaires replace erectile dysfunction testing?. Urology. 1999;54(4):719-723. [pmid: 10510935].
Boccon Gibod L. Is transurethral needle ablation a safe and effective treatment for lower urinary tract symptoms secondary to BPH?. Nature Clinical Practice Urology. 2004;1(1):24-25.
Bochinski DJ, Dean RC, Lue TF. Erectile dysfunction and priapism. Nat Clin Pract Urol. 2004;1(1):49-53. [pmid: 16474467].
Bodie JA, Beeman WW, Monga M. Psychogenic erectile dysfunction. Int J Psychiatry Med. 2003;33(3):273-293. [pmid: 15089008].
Bodie J, Lewis J, Schow D, et al. Laboratory evaluations of erectile dysfunction: an evidence based approach. Br J Urol. 2003;169(6):2262-2264.
Bodner DR, Leffler B, Frost F. The role of intracavernous injection of vasoactive medications for the restoration of erection in spinal cord injured males: a three year follow up. Paraplegia. 1992;30(2):118-120. [pmid: 1589286].
Bolona ER, Uraga MV, Haddad RM, et al. Testosterone use in men with sexual dysfunction: a systematic review and meta-analysis of randomized placebo-controlled trials. Mayo Clin Proc. 2007;82(1):20-28. [pmid: 17285782].
Boolell M, Allen MJ, Ballard SA, et al. Sildenafil: an orally active type 5 cyclic GMP-specific phosphodiesterase inhibitor for the treatment of penile erectile dysfunction. Int J Impot Res. 1996;8(2):47-52. [pmid: 8858389].
Boshier A, Wilton LV, Shakir SAW. Evaluation of the safety of sildenafil for male erectile dysfunction: Experience gained in general practice use in England in 1999. BJU Int. 2004;93(6):796-801. [pmid: 15049992].
Bouloux P. Testim 1% testosterone gel for the treatment of male hypogonadism. [Review] [33 refs]. Clin Ther. 2005;27(3):286-298. [pmid: 15878382].
Boydak B, Nalbantgil S, Fici F, et al. A randomised comparison of the effects of nebivolol and atenolol with and without chlorthalidone on the sexual function of hypertensive men. Clinical Drug Investigation. 2005;25(6):409-416. [pmid: 17532681].
Braatvedt GD. Outcome of managing impotence in clinical practice. N Z Med J. 1999;112(1092):272-274. [pmid: 10472891].
Brake M, Loertzer H, Horsch R, et al. Treatment of Peyronie's disease with local interferon-alpha 2b. BJU Int. 2001;87(7):654-657. [pmid: 11350406].
Bratus D, Hlebic G, Hajdinjak T. 16905960 of erectile dysfunction. Croat Med J. 2007;48(1):76-80. [pmid: 17309142].
Brazil M. Viagra for broken hearts?. Nat Rev Genet. 2005;4(3):190.
Brennemann W, Kohler W, Zierz S, et al. Testicular dysfunction in adrenomyeloneuropathy. Eur J Endocrinol. 1997;137(1):34-39. [pmid: 9242199].
Brennemann W, Stitz B, Van Ahlen H, et al. Treatment of idiopathic erectile dysfunction in men with the opiate antagonist naltrexone—a double-blind study. J Androl. 1993;14(6):407-410. [pmid: 8294223].
Briganti A, Chun FKH, Salonia A, et al. A comparative review of apomorphine formulations for erectile dysfunction: Recommendations for use in the elderly. Drugs Aging. 2006;23(4):309-319. [pmid: 16732690].
Briganti A, Salonia A, Gallina A, et al. Drug insight: Oral phosphodiesterase type 5 inhibitors for erectile dysfunction. Nature Clinical Practice Urology. 2005;2(5):239-247.
Briganti A, Salonia A, Zanni G, et al. Erectile dysfunction and radical prostatectomy: An update. Eau Update Series. 2004;2(2):84-92.
Brindis RG, Kloner RA. Sildenafil in patients with cardiovascular disease. [Review] [33 refs]. Am J Cardiol. 2003;92(9A):26M-36M. [pmid: 12842240].
Brixius K, Middeke M, Lichtenthal A, et al. Nitric oxide, erectile dysfunction and beta-blocker treatment (MR NOED study): Benefit of nebivolol versus metoprolol in hypertensive men. Clinical & Experimental Pharmacology & Physiology. 2007;34(4):327-331. [pmid: 17324145].
Broderick GA, Allen G, McClure RD. Vacuum tumescence devices: the role of papaverine in the selection of patients. Br J Urol. 1991;145(2):284-286.
Brooks D P, Giuliano F. Genitourinary diseases. Drug Discovery Today: Therapeutic Strategies 2005;2(1):iii-iiv.
Brown JS, Wessells H, Chancellor MB, et al. Urologic complications of diabetes. Diabetes Care. 2005;28(1):177-185. [pmid: 15616253].
Buchholz NP, Weuste R, Mattarelli G, et al. Post-vasectomy erectile dysfunction. J Psychosom Res. 1994;38(7):759-762. [pmid: 7877130].
Buddeberg C, Bucher T, Hornung R. [Erectile dysfunction in men in their second half of life]. Urologe 2005;Ausg. A. 44(9):1045–1046, 1048–51.
Buena F, Swerdloff RS, Steiner BS, et al. Sexual function does not change when serum testosterone levels are pharmacologically varied within the normal male range. Fertility & Sterility. 1993;59(5):1118-1123. [pmid: 8486184].
Bukofzer S, Livesey N. Safety and tolerability of apomorphine SL (Uprima). Int J Impot Res. 2001;13(SUPPL. 3):S40-S44. [pmid: 11477491].
Burls A, Gold L, Clark W. Systematic review of randomised controlled trials of sildenafil (Viagra) in the treatment of male erectile dysfunction. Br J Gen Pract. 2001;51(473):1004-1012. [pmid: 11766850].
Burnett AL. Efficacy of tadalafil for the treatment of erectile dysfunction at 24 and 36 hours after dosing: A randomized controlled trial: Editorial comment 2. Urology. 2003;62(1):126.
Burnett AL. Vasoactive pharmacotherapy to cure erectile dysfunction: fact or fiction?. [Review] [45 refs]. Urology. 2005;65(2):224-230. [pmid: 15708027].
Burnett AL. The impact of sildenafil on molecular science and sexual health. Eur Urol. 2004;46(1):9-14. [pmid: 15183543].
Burns-Cox N, Gingell C. The andropause: fact or fiction?. [Review] [49 refs]. Postgrad Med J. 1997;73(863):553-556. [pmid: 9373594].
Buvat J. Hyperprolactinemia and sexual function in men: a short review. [Review] [26 refs]. Int J Impot Res. 2003;15(5):373-377. [pmid: 14562140].
Buvat J, Boujadoue G. Testosterone replacement therapy in the ageing man. The Journal of Mens Health & Gender. 2005;2(4):396-399.
Calof OM, Singh AB, Lee ML, et al. Adverse events associated with testosterone replacement in middle-aged and older men: A meta-analysis of randomized, placebo-controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60(11):1451-1457.
Campbell M. Beneficial cardiovascular effects and safety of sildenafil reported in trio of studies. Cardiology Review. 2001;18(6):27.
Cappelleri JC, Siegel RL, Glasser DB, et al. Relationship between patient self-assessment of erectile dysfunction and the sexual health inventory for men. Clin Ther. 2001;23(10):1707-1719. [pmid: 11726005].
Cara AM, Lopes-Martins RAB, Antunes E, et al. The role of histamine in human penile erection. Br J Urol. 1995;75(2):220-224. [pmid: 7850330].
Carani C, Bancroft J, Granata A, et al. Testosterone and erectile function, nocturnal penile tumescence and rigidity, and erectile response to visual erotic stimuli in hypogonadal and eugonadal men. Psychoneuroendocrinology. 1992;17(6):647-654. [pmid: 1287683].
Carani C, Scuteri A, Marrama P, et al. The effects of testosterone administration and visual erotic stimuli on nocturnal penile tumescence in normal men. Horm Behav. 1990;24(3):435-441. [pmid: 2227854].
Cardenas DD, Ditunno J, Graziani V, et al. Phase 2 trial of sustained-release fampridine in chronic spinal cord injury. Proc Annu Clin Spinal Cord Inj Conf. 2007;45(2):158-168.
Carey MP, Johnson BT. Effectiveness of yohimbine in the treatment of erectile disorder: four meta-analytic integrations. Arch Sex Behav. 1996;25(4):341-360. [pmid: 8836468].
Carey Michael P, Wincze John P, Meisler Andrew W. Sexual dysfunction: Male erectile disorder. Barlow, David H (Ed) 1993;(1993):534
Carosa E, Benvenga S, Trimarchi F, et al. Sexual inactivity results in reversible reduction of LH bioavailability. Int J Impot Res. 2002;14(2):93-99. [pmid: 11979323].
Carson CC. PNU-83757: a new agent for the treatment of erectile dysfunction.[comment]. Curr Urol Rep. 2002;3(6):465-466. [pmid: 12425868].
Carson CC, Burnett AL, Levine LA, et al. The efficacy of sildenafil citrate (Viagra) in clinical populations: an update. Urology. 2002;60(2 Suppl 2):12-27. [pmid: 12414330].
Carson CC, Hatzichristou DG, Carrier S. Erratum: Erectile response with vardenafil in sildenafil nonresponders: A multicentre, double-blind, 12-week, flexible-dose, placebo-controlled erectile dysfunction clinical trial (BJU International (2004) 94 (1301–1309)). BJU Int. 2005;96(3):466.
Carson CC, Rajfer J, Eardley I, et al. The efficacy and safety of tadalafil: an update. BJU Int. 2004;93(9):1276-1281. [pmid: 15180622].
Casella R, Deckart A, Bachmann A, et al. The patient's self-evaluation better predicts the degree of erectile dysfunction than the response to intracavernous alprostadil testing. Urol Int. 2004;72(3):216-220. [pmid: 15084765].
Caspi A, Goldenberg M M. Sildenafil: A new drug treatment for male erectile dysfunction. P & T 1998;23(5):
Cawello W, Schweer H, Dietrich B, et al. Pharmacokinetics of prostaglandin E1 and its main metabolites after intracavernous injection and short-term infusion of prostaglandin E1 in patients with erectile dysfunction. Br J Urol. 1997;158(4):1403-1407.
Cecchi M, Sepich CA, Felipetto R, et al. Vacuum constriction device and topical minoxidil for management of impotence. Arch Esp Urol. 1995;48(10):1058-1059. [pmid: 8588728].
Chaiban JT, Azar ST. Erectile dysfunction in diabetic patients. J Med Liban. 2004;52(4):217-219. [pmid: 16432985].
Chang DW, Wood CG, Kroll SS, et al. Cavernous nerve reconstruction to preserve erectile function following non-nerve-sparing radical retropubic prostatectomy: a prospective study. Keisei Geka. 2003;111(3):1174-1181.
Chatterjee R, Andrews HO, McGarrigle HH, et al. Cavernosal arterial insufficiency is a major component of erectile dysfunction in some recipients of high-dose chemotherapy/chemoradiotherapy for haematological malignancies. Bone Marrow Transplant. 2000;25(11):1185-1189. [pmid: 10849531].
Chatterjee R, Kottaridis PD, McGarrigle HH, et al. Management of erectile dysfunction by combination therapy with testosterone and sildenafil in recipients of high-dose therapy for haematological malignancies. Bone Marrow Transplant. 2002;29(7):607-610. [pmid: 11979311].
Chaudhuri TK, Fink S, Burger RH, et al. Nuclear penogram: Non-invasive technique to monitor and record effect of pharmacologically-induced penile erection in impotence therapy. Urology. 1990;35(1):98. [pmid: 2296828].
Cheitlin MD, Hutter AM, Brindis RG, et al. Use of sildenafil (Viagra) in patients with cardiovascular disease. Circulation. 1999;99(1):168-177. [pmid: 9884398].
Chen CT, Valicenti RK, Lu J, et al. Does hormonal therapy influence sexual function in men receiving 3D conformal radiation therapy for prostate cancer?. Int J Radiat Oncol Biol Phys. 2001;50(3):591-595. [pmid: 11395224].
Chen J, Greenstein A, Kaver I, et al. Use of automatic insulin injector for intracorporeal injection in erectile dysfunction. Br J Urol. 1994;152(2):461-462.
Chen J, Mabjeesh NJ, Greenstein A. Sildenafil versus the vacuum erection device: patient preference. Br J Urol. 2001;166(5):1779-1781.
Chen J, Wollman Y, Chernichovsky T, et al. Effect of oral administration of high-dose nitric oxide donor L-arginine in men with organic erectile dysfunction: results of a double-blind, randomized, placebo-controlled study. BJU Int. 1999;83(3):269-273. [pmid: 10233492].
Chen KC, Minor TX, Rahman NU, et al. The additive erectile recovery effect of brain-derived neurotrophic factor combined with vascular endothelial growth factor in a rat model of neurogenic impotence. BJU Int. 2005;95(7):1077-1080. [pmid: 15839936].
Chen KK, Jiann BP, Lin JSN, et al. Erratum: Efficacy and safety of on- demand oral tadalafil in the treatment of men eith erectile dysfunction in Taiwan: A randomized, double- blind, parallel, placebo- conrolled clinical study (Journal of Sexual Medicine vol. 1 (2)). Br J Sex Med. 2005;2(1):158.
Cheng JYW, Ng EML, Chen RYL, et al. Prevalence of erectile dysfunction in Asian populations: A meta-analysis. Int J Impot Res. 2007;19(3):229-244. [pmid: 16929338].
Chew KK. Prevalence of hypogonadism in the aging male and male erectile dysfunction in Asia-Pacific countries. Asian J Androl. 2003;5(2):171-172.
Chew KK, Stuckey BG. Clinical course of penile fibrosis in intracavernosal prostaglandin E1 injection therapy: a follow-up of 44 patients. Int J Impot Res. 2003;15(2):94-98. [pmid: 12789387].
Chew KK, Stuckey BGA. Use of transurethral alprostadil (MUSE) (prostaglandin E1) for glans tumescence in a patient with penile prosthesis. Int J Impot Res. 2000;12(3):195-196. [pmid: 11045915].
Chew KK, Stuckey BGA, Thompson PL. Erectile dysfunction, sildenafil and cardiovascular risk. Med J Aust. 2000;172(6):279-283. [pmid: 10860094].
Chia S. Management of premature ejaculation — a comparison of treatment outcome in patients with and without erectile dysfunction. Int J Androl. 2002;25(5):301-305. [pmid: 12270028].
Chinegwundoh F, Anie K A. Treatments for priapism in boys and men with sickle cell disease. [Review][16 refs]. Cochrane Database Syst Rev 2004;(4):CD004198
Chiu KC, Cohan P, Martinez D, et al. Adrenal insufficiency after medical therapy for prolactin and adrenocorticotropic hormone co-producing pituitary macroadenoma without hypercortisolism. Endocr Pract. 2001;11(6):443-446.
Chiu YJ, Reid IA. Effect of sildenafil on renin secretion in human subjects. Experimental biology and medicine (Maywood, NJ). 2002;227(8):620-625.
Christ B, Brockmeier D, Hauck EW, et al. Interactions of sildenafil and tacrolimus in men with erectile dysfunction after kidney transplantation. Urology. 2001;58(4):589-593. [pmid: 11597545].
Christ GJ, Melman A. The application of gene therapy to the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):111-112. [pmid: 9647947].
Chue P. Gabapentin treatment for premature ejaculation [3]. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 2004;49(9):644-645. [pmid: 15503740].
Cimentepe E, Unsal A, Saglam R. Randomized clinical trial comparing transurethral needle ablation with transurethral resection of the prostate for the treatment of benign prostatic hyperplasia: results at 18 months. J Endourol. 2003;17(2):103-107. [pmid: 12689404].
Clark C. Erectile dysfunction and other problems. Can Pharm J. 2004;272(7299):608-610.
Clark RV, Hermann DJ, Cunningham GR, et al. Marked Suppression of Dihydrotestosterone in Men with Benign Prostatic Hyperplasia by Dutasteride, a Dual 5a-Reductase Inhibitor. Journal of Clinical Endocrinology & Metabolism. 2004;89(5):2179-2184. [pmid: 15126539].
Claro JA, Passerotti CC, Figueiredo Neto AC, et al. An alternative non-invasive treatment for Peyronie's disease. International Braz J Urol. 2004;30(3):199-204. [pmid: 15689246].
Clough J. CNS-targeted sexual dysfunction drug for men and women. Drug Discov Today. 2002;7(9):492-494. [pmid: 11983559].
Coelho OR. Tolerability and safety profile of sildenafil citrate (Viagra) in Latin American patient populations. Int J Impot Res. 2002;14(Suppl 2):54-59. [pmid: 11896479].
Coker C, Bettocchi C, Pryor J. Caverject, a new licensed prostaglandin preparation for use in erectile dysfunction. J Androl. 1994;15(6 SUPPL.):71S.
Coleman CI, Carabino JM, Vergara CM, et al. Vardenafil. Hosp Formul. 2003;38(3):131-148.
Collazos J, Martinez E, Mayo J, et al. Sexual dysfunction in HIV-infected patients treated with highly active antiretroviral therapy. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2002;31(3):322-326. [pmid: 12439208].
Colp GM, Scroppo FI. Can self-directed pelvic floor exercises improve erectile function?. Nature Clinical Practice Urology. 2005;2(3):128-129.
Conti CR, Pepine CJ, Sweeney M. Efficacy and safety of sildenafil citrate in the treatment of erectile dysfunction in patients with ischemic heart disease. Am J Cardiol. 1999;83(5A):29C-34C.
Contreras LN, Masini AM, Danna MM, et al. Glucocorticoids: their role on gonadal function and LH secretion. Minerva Endocrinol. 1996;21(2):43-46. [pmid: 8968148].
Cooper AJ, Losztyn S, Russell NC, et al. Medroxyprogesterone acetate, nocturnal penile tumescence, laboratory arousal, and sexual acting out in a male with schizophrenia. Arch Sex Behav. 1990;19(4):361-372. [pmid: 2144727].
Cormio L, Nisen H, Ruutu M, et al. Etilefrine in the prevention of prolonged erection after diagnostic pharmacological stimulation. Ann Chir Gynaecol. 1996;85(3):247-250. [pmid: 8950448].
Corona G, Mannucci E, Fisher AD, et al. Effect of hyperprolactinemia in male patients consulting for sexual dysfunction. Br J Sex Med. 2007;4(5):1485-1493.
Corona G, Mannucci E, Petrone L, et al. ANDROTEST: a structured interview for the screening of hypogonadism in patients with sexual dysfunction. Br J Sex Med. 2006;3(4):706-715.
Corona G, Mannucci E, Petrone L, et al. Association of hypogonadism and type II diabetes in men attending an outpatient erectile dysfunction clinic. Int J Impot Res. 2006;18(2):190-197. [pmid: 16136189].
Corona G, Mannucci E, Schulman C, et al. Psychobiologic correlates of the metabolic syndrome and associated sexual dysfunction. Eur Urol. 2006;50(3):595-604. [pmid: 16564129].
Creasey GH. Lecture 6: restoration of male sexual function following spinal cord injury. Int J Impot Res. 2000;12(Suppl 3):S54-S55. [pmid: 11002403].
Crowe SM, Streetman DS. Vardenafil treatment for erectile dysfunction. [Review] [43 refs]. Ann Pharmacother. 2004;38(1):77-85. [pmid: 14742800].
Crum-Cianflone NF, Bavaro M, Hale B, et al. Erectile dysfunction and hypogonadism among men with HIV. AIDS Patient Care & Stds. 2007;21(1):9-19. [pmid: 17263654].
Culha M, Mutlu N, Acar O, et al. Patient-partner satisfaction with intracavernous medication supported with oral agents in selected cases of Peyronie's disease: A ten-month follow-up study. International Urology & Nephrology. 1999;31(2):257-262. [pmid: 10481972].
Curran M, Keating G. Tadalafil.[erratum appears in Drugs. 2003;63(23):2703]. [Review] [31 refs]. Drugs. 2003;63(20):2203-2212. [pmid: 14498756].
Curri SB, Menchini Fabris F. Evidence and results obtained with a new Trans-Epidermal Barrier (T.E.B.) drug in the medical treatment of vascular impotence. Boll Chim Farm. 1996;135(5):316-334. [pmid: 8942060].
Cyranoski D. Malaysian researchers bet big on home-grown Viagra. Nat Med. 2005;11(9):912. [pmid: 16145563].
Czuriga I, Riecansky I, Bodnar J, et al. Comparison of the New Cardioselective Beta-Blocker Nebivolol with Bisoprolol in Hypertension: The Nebivolol, Bisoprolol Multicenter Study (NEBIS). Cardiovascular Drugs & Therapy. 2003;17(3):257-263. [pmid: 14574084].
Dang G, Matern R, Bivalacqua TJ, et al. Intralesional interferon-alpha-2B injections for the treatment of Peyronie's disease. South Med J. 2004;97(1):42-46. [pmid: 14746421].
Davis BE, Weigel JW, Whitford CS. Treatment of male impotence: a new option. Kans Med. 1990;91(12):325-326. [pmid: 1705298].
Davis JM. American College of Neuropsychopharmacology - 43rd annual meeting. 12–16 December 2004, San Juan, Puerto Rico. IDrugs. 2005;8(2):100-103. [pmid: 15696406].
Davis ME, Brewster ME. Cyclodextrin-based pharmaceutics: Past, present and future. Nat Rev Genet. 2004;3(12):1023-1035.
De Meyer JM, Oosterlinck W. Influence of the method of intracavernous injection on penile rigidity: a possible pharmacokinetic explanation. Urology. 1997;49(2):248-252. [pmid: 9037289].
De Tejada I. Vardenafil Duration of Action. Eur Urol. 2006;50(5):901-902. [pmid: 16949729].
De Tejada I, Garvey DS, Schroeder JD, et al. Design and evaluation of nitrosylated alpha-adrenergic receptor antagonists as potential agents for the treatment of impotence. Journal of Pharmacology & Experimental Therapeutics. 1999;290(1):121-128. [pmid: 10381767].
Degirmenci B, Acar M, Albayrak R, et al. Effects of sildenafil citrate (Viagra) on renal arteries: An evaluation with Doppler ultrasound. Urol Int. 2006;77(2):170-172. [pmid: 16888425].
Del Popolo G, Li Marzi V, Mondaini N, et al. Time/duration effectiveness of sildenafil versus tadalafil in the treatment of erectile dysfunction in male spinal cord-injured patients. Proc Annu Clin Spinal Cord Inj Conf. 2004;42(11):643-648.
Delizonna LL, Wincze JP, Litz BT, et al. A comparison of subjective and physiological measures of mechanically produced and erotically produced erections (or, is an erection an erection?). J Sex Marital Ther. 2001;27(1):21-31. [pmid: 11224951].
Denisov MF, Davis JM, Brecher M. Re: Prolactin levels and adverse events in patients treated with risperidone [8] (multiple letters). J Clin Psychopharmacol. 2002;22(5):538-540. [pmid: 12352286].
Derby CA, Araujo AB, Johannes CB, et al. Measurement of erectile dysfunction in population-based studies: the use of a single question self-assessment in the Massachusetts Male Aging Study. Int J Impot Res. 2000;12(4):197-204. [pmid: 11079360].
Derby CA, Barbour MM, Hume AL, et al. Drug therapy and prevalence of erectile dysfunction in the Massachusetts Male Aging Study cohort. Pharmacotherapy. 2001;21(6):676-683. [pmid: 11401181].
Derouet H, Nolden W, Jost WH, et al. Treatment of erectile dysfunction by an external ischiocavernous muscle stimulator. Eur Urol. 1998;34(4):355-359. [pmid: 9748685].
Desouza C, Parulkar A, Lumpkin D, et al. Acute and prolonged effects of sildenafil on brachial artery flow-mediated dilatation in type 2 diabetes. Diabetes Care. 2002;25(8):1336-1339. [pmid: 12145231].
Dietzen CJ, Lloyd LK. Complications of intracavernous injections and penile prostheses in spinal cord injured men. Archives of Physical Medicine & Rehabilitation. 1992;73(7):652-655. [pmid: 1622321].
Dinelli N, Salinitri G, Pomara G, et al. Role of pharmacologic rehabilitation in the recovery of sexual function following radical prostatectomy. Minerva Urol Nefrol. 2005;57(4):325-329. [pmid: 16247354].
Dinsmore WW. Medical treatment of impotence with papaverine and phentolamine intracavernosal injection. Ulster Med J. 1990;59(2):174-176. [pmid: 2278115].
Dinsmore WW, Gingell C, Hackett G, et al. Treating men with predominantly nonpsychogenic erectile dysfunction with intracavernosal vasoactive intestinal polypeptide and phentolamine mesylate in a novel auto-injector system: a multicentre double-blind placebo-controlled study. BJU Int. 1999;83(3):274-279. [pmid: 10233493].
Djavan B, Milani S, Fong YK. Dutasteride: A novel dual inhibitor of 5a-reductase for benign prostatic hyperplasia. Expert Opin Pharmacother. 2005;6(2):311-317. [pmid: 15757426].
Doggrell SA. Comparison of clinical trials with sildenafil, vardenafil and tadalafil in erectile dysfunction. Expert Opin Pharmacother. 2005;6(1):75-84. [pmid: 15709885].
Donatucci CF, Lue TF. Erectile dysfunction in men under 40: etiology and treatment choice. Int J Impot Res. 1993;5(2):97-103. [pmid: 8348217].
Doumas M, Tsakiris A, Douma S, et al. Beneficial effects of switching from beta-blockers to nebivolol on the erectile function of hypertensive patients. Asian J Androl. 2006;8(2):177-182. [pmid: 16491268].
Dundar SO. Visual loss associated with erectile dysfunction drugs. Can J Ophthalmol. 2007;42(1):10-12. [pmid: 17361234].
Dupont Simon. Multiple sclerosis and sexual functioning: A review. Clin Rehabil. 1995;9(2):135-141.
Durackova Z, Trebaticky B, Novotny V, et al. Lipid metabolism and erectile function improvement by Pycnogenol, extract from the bark of Pinus pinaster in patients suffering from erectile dysfunction - A pilot study. Adv Food Nutr Res. 2003;23(9):1189-1198.
Eandi J A, Yao A P, Javidan J. Penile paraffinoma: the delayed presentation. Int Urol Nephrol 2007;
Eardley I. New oral therapies for the treatment of erectile dysfunction. Br J Urol. 1998;81(1):122-127. [pmid: 9467488].
Earle CM, Keogh EJ, Ker JK, et al. The role of intracavernosal vasoactive agents to overcome impotence due to spinal cord injury. Paraplegia. 1992;30(4):273-276. [pmid: 1625897].
Earle CM, Stuckey BG, Ching HL, et al. The incidence and management of priapism in Western Australia: a 16 year audit. Int J Impot Res. 2003;15(4):272-276. [pmid: 12934055].
Edwards G, Muirhead GJ. British Journal of Clinical Pharmacology: Introduction. Br J Clin Pharmacol. 2002;53(SUPPL. 1):1S-3S.
Ekmekcioglu O, Inci M, Demirci D, et al. Effects of sildenafil citrate on ejaculation latency, detumescence time, and refractory period: placebo-controlled, double-blind, crossover laboratory setting study. Urology. 2005;65(2):347-352. [pmid: 15708051].
Ekselius L, Von Knorring L. Effect on sexual function of long-term treatment with selective serotonin reuptake inhibitors in depressed patients treated in primary care. J Clin Psychopharmacol. 2001;21(2):154-160. [pmid: 11270911].
El Malik EMA. Erectile dysfunction: An update of diagnosis and management. Qatar Medical Journal. 2000;9(2):9-17.
El-Bahnasawy MS, El-Assmy A, Dawood A, et al. Effect of the use of internal iliac artery for renal transplantation on penile vascularity and erectile function: A prospective study. Br J Urol. 2004;172(6 I):2335-2339.
El-Rufaie Omer EF, Bener Abdulbari, Abuzeid Mohamed SO, et al. Sexual dysfunction among type II diabetic men: A controlled study. J Psychosom Res. 1997;43(6):605-612. [pmid: 9430073].
El-Sakka AI. Penile axial rigidity and Doppler ultrasonography parameters in patients with erectile dysfunction: association with type 2 diabetes. Urology. 2003;62(3):525-531. [pmid: 12946761].
Emilien G. Alprox-TD NexMed Inc. Current Opinion in Central & Peripheral Nervous System Investigational Drugs 2000;2(3):311–320.
Ende AR, Lo Re V, DiNubile MJ, et al. Erectile dysfunction in an urban HIV-positive population. AIDS Patient Care & Stds. 2006;20(2):75-78. [pmid: 16475887].
Engelhardt PF, Daha LK, Zils T, et al. Acupuncture in the treatment of psychogenic erectile dysfunction: first results of a prospective randomized placebo-controlled study. Int J Impot Res. 2003;15(5):343-346. [pmid: 14562135].
Engelson ES, Pi-Sunyer FX, Kotler DP. Effects of megestrol acetate therapy on body composition and circulating testosterone concentrations in patients with AIDS. Int J STD AIDS. 1995;9(9):1107-1108.
Engl T, Beecken WD, Wolfram M, et al. Uropharmacology: Current and future strategies in the treatment of erectile dysfunction and benign prostate hyperplasia. International Journal of Clinical Pharmacology & Therapeutics. 2004;42(10):527-533. [pmid: 15516021].
English JC, King DHC, Foley JP. Penile shaft hypopigmentation: Lichen sclerosus occurring after the initiation of alprostadil intracavernous injections for erectile dysfunction. J Am Acad Dermatol. 1998;39(5 I):801-803. [pmid: 9810901].
Ensign C. First-line therapies for erectile dysfunction. [Review] [8 refs]. JAAPA. 2001;14(10):17-20. [pmid: 11715672].
Erdogru T, Kocak T, Serdaroglu P, et al. Evaluation and therapeutic approaches of voiding and erectile dysfunction in neurological Behcet's syndrome. Br J Urol. 1999;162(1):147-153.
Ernst E. Chinese herbal medicines for consumers in the West. Focus on Alternative & Complementary Therapies. 2005;10(2):94-97.
Ernst E, Pittler MH. Yohimbine for erectile dysfunction: a systematic review and meta-analysis of randomized clinical trials. J Urol. 1998;159(2):433-436. [pmid: 9649257].
Escobar-Jimenez F. [Efficacy and safety of sildenafil in men with type 2 diabetes mellitus and erectile dysfunction]. Med Clin (Barc). 2002;119(4):121-124. [pmid: 12106522].
Esposito K, Giugliano F, Martedi E, et al. High proportions of erectile dysfunction in men with the metabolic syndrome. Diabetes Care. 2005;28(5):1201-1203. [pmid: 15855589].
Evans M F. Viagra! Are we ready?. Can Fam Physician. 1998;44:2103-2105. [pmid: 9805164].
Fagan Peter J, Blum Lois H. Issues in the psychotherapeutic treatment of sexual dysfunction following radical retropubic prostatectomy. Rosen, Raymond C (Ed); Leiblum, Sandra R (Ed) 1995;(1995):400
Fagan TC, Buttler S, Marbury T, et al. Cardiovascular safety of sublingual apomorphine in patients on stable doses of oral antihypertensive agents and nitrates. Am J Cardiol. 2001;88(7):760-766. [pmid: 11589843].
Faiman C. Endocrine causes of impotence. Cleve Clin J Med. 1993;60(6):428-429. [pmid: 7507006].
Fazeli-Matin S, Montague DK, Angermeier KW, et al. Penile fracture after intracavernous injection therapy. Br J Urol. 1998;159(6):2094.
Fedele D, Coscelli C, Cucinotta D, et al. Management of erectile dysfunction in diabetic subjects: results from a survey of 400 diabetes centres in Italy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14(5):277-282.
Fedele D, Lamonica M, Bax G. Experience with sildenafil in diabetes. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):49-52.
Fekete F, Fabian E. [Effectiveness and adverse effects of sildenafil in erectile dysfunction]. Orv Hetil. 2000;141(3):115-118. [pmid: 10693332].
Feldman HA, Goldstein I, Hatzichristou DG, et al. Impotence and its medical and psychosocial correlates: results of the Massachusetts Male Aging Study. Br J Urol. 1994;151(1):54-61.
Feldman HA, Johannes CB, Derby CA, et al. Erectile dysfunction and coronary risk factors: prospective results from the Massachusetts male aging study. Prev Med. 2000;30(4):328-338. [pmid: 10731462].
Fink HA, Mac Donald R, Rutks IR, et al. Sildenafil for male erectile dysfunction: a systematic review and meta-analysis. Arch Intern Med. 2002;162(12):1349-1360. [pmid: 12076233].
Fink HA, MacDonald R, Rutks IR, et al. Trazodone for erectile dysfunction: a systematic review and meta-analysis. BJU Int. 2003;92(4):441-446. [pmid: 12930437].
Finkbeiner A. Random musing about a little blue pill. J Ark Med Soc. 1998;95(3):100-101. [pmid: 9735630].
Fishbain David A. Impact of sildenafil on male erectile disorder due to psychological factors. Can J Psychiatry. 2000;45(1):85-86. [pmid: 10696497].
Fisher WA, Rosen RC, Eardley I, et al. The Multinational Men's Attitudes to Life Events and Sexuality (MALES) Study Phase II: Understanding PDE5 inhibitor treatment seeking patterns, among men with erectile dysfunction. Br J Sex Med. 2004;1(2):150-160.
Flack JM. The effect of doxazosin on sexual function in patients with benign prostatic hyperplasia, hypertension, or both.[see comment]. [Review] [47 refs]. Int J Clin Pract. 2002;56(7):527-530. [pmid: 12296615].
Foresta C, Caretta N, Rossato M, et al. Role of androgens in erectile function. Br J Urol. 2004;171(6 Pt 1):2358-2362.
Foulks CJ, Cushner HM. Sexual dysfunction in the male dialysis patient: pathogenesis, evaluation, and therapy. [Review] [105 refs]. Am J Kidney Dis. 1986;8(4):211-222. [pmid: 3532769].
Frank T. Tadalafil (Cialis-Lilly). Consultant Pharmacist. 2004;19(4):280-281.
Frank T. Vardenafil (Levitra-Bayer) GSK. Consultant Pharmacist. 2004;19(4):278-280.
Franzen D, Metha A, Seifert N, et al. Effects of beta-blockers on sexual performance in men with coronary heart disease. A prospective, randomized and double blinded study. Int J Impot Res. 2001;13(6):348-351. [pmid: 11918251].
Fraunfelder F W, Fraunfelder F T. Scientific Challenges in Postmarketing Surveillance of Ocular Adverse Drug Reactions. Am J Ophthalmol 2007;143(1):
Freemantle N. Valuing the effects of sildenafil in erectile dysfunction. Br Med J. 2000;320(7243):1156-1157. [pmid: 10784525].
Freytag SO, Stricker H, Pegg J, et al. Phase I Study of Replication-Competent Adenovirus-Mediated Double-Suicide Gene Therapy in Combination with Conventional-Dose Three-Dimensional Conformal Radiation Therapy for the Treatment of Newly Diagnosed, Intermediate- to High-Risk Prostate Cancer. Cancer Res. 2003;63(21):7497-7506. [pmid: 14612551].
Fu Q, Yao DH, Jiang YQ. Effect of sodium nitroprusside on hemodynamics of corpus cavernosum in Chinese. Asian J Androl. 2001;3(4):311-313. [pmid: 11753478].
Fugl-Meyer AR, Lodnert G, Branholm IB, et al. On life satisfaction in male erectile dysfunction. Int J Impot Res. 1997;9(3):141-148. [pmid: 9315491].
Fulgram PF, Cochran JS, Denman JL, et al. Re: Disappointing initial results with transurethral alprostadil for erectile dysfunction in a urology practice setting [5]. Br J Urol. 1999;162(4):1390.
Gallo L, Perdona S, Autorino R, et al. Recovery of erection after pelvic urologic surgery: our experience. Int J Impot Res. 2005;17(6):484-493. [pmid: 15889123].
Gerstenbluth RE, Maniam PN, Corty EW, et al. Prostate-specific antigen changes in hypogonadal men treated with testosterone replacement. J Androl. 2002;23(6):922-926. [pmid: 12399540].
Ghezzi A, Malvestiti GM, Baldini S, et al. Erectile impotence in multiple sclerosis: A neurophysiological study. J Neurol. 1995;242(3):123-126. [pmid: 7751853].
Giammusso B, Gattuso U, Vanaclocha V, et al. Percutaneous lumbar sympathectomy in the treatment of erectile dysfunction secondary to cavernous adrenergic hypertone: initial results of an original technique. Arch Ital Urol Androl. 2005;77(1):5-9. [pmid: 15906781].
Giampietro O, Ferdeghini M, Cerri M, et al. Evaluation of the hypothalamic-pituitary-testicular interaction in diabetic males. European J Lab Med. 1994;2(2):83-89.
Gillies HC, Roblin D, Jackson G. Coronary and systemic hemodynamic effects of sildenafil citrate: From basic science to clinical studies in patients with cardiovascular disease. Int J Cardiol. 2002;86(23):131-141. [pmid: 12419549].
Ginsberg DL. Gabapentin treatment of premature ejaculation. Primary Psychiatry. 2004;11(12):20-21.
Ginsberg DL. Vardenafil treatment of sertraline-induced sexual dysfunction. Primary Psychiatry. 2004;11(11):23-24.
Ginsberg David L. Sildenafil-dihydrocodeine interaction results in prolonged erections. [References]. Primary Psychiatry. 2003;10(2):23.
Ginzburg R, Wong Y, Fader JS. Effect of bupropion on sexual dysfunction. Ann Pharmacother. 2005;39(12):2096-2099. [pmid: 16288071].
Giuberti A, Picozzi SC, Mazza L, et al. Testosterone supplementation in hypogonadal men: our personal experience. Arch Ital Urol Androl. 2005;77(4):191-193. [pmid: 16444930].
Giuliano F. Control of penile erection by the melanocortinergic system: Experimental evidences and therapeutic perspectives. J Androl. 2004;25(5):683-691. [pmid: 15292097].
Giuliano F, Allard J, Rampin O, et al. Pro-erectile effect of systemic apomorphine: Existence of a spinal site of action. Br J Urol. 2002;167(1):402-406.
Giuliano F, Hultling C, El Masry WS, et al. Randomized trial of sildenafil for the treatment of erectile dysfunction in spinal cord injury. Sildenafil Study Group. Ann Neurol. 1999;46(1):15-21. [pmid: 10401776].
Giuliano F, Pena BM, Mishra A, et al. Efficacy results and quality-of-life measures in men receiving sildenafil citrate for the treatment of erectile dysfunction. Qual Life Res. 2001;10(4):359-369. [pmid: 11763248].
Giuliano Francois, Pena Beatrice, Mishra Avanish, et al. “Efficacy results and quality-of-life measures in men receiving sildenafil citrate for the treatment of erectile dysfunction”: Erratum. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care & Rehabilitation. 2002;11(6):613-670.
Gladh YM, Rahgozar M, Hammar ML, et al. Prevalence of symptoms possibly related to PADAM, in a Swedish population aged 55, 65 and 75 years. Maturitas. 2005;50(3):161-166. [pmid: 15734596].
Glasser SP. Revisiting erectile dysfunction in cardiovascular patients. Cardiology Review. 2003;20(12):42-43.
Glasser SP. Safety of PDE 5 inhibition in patients with cardiovascular disease. Cardiology Review. 2002;19(11):32-33.
Glenn DRJ, McClure N, Lewis SEM. The hidden impact of diabetes on male sexual dysfunction and fertility. Hum Fertil. 2003;6(4):174-179.
Goldenberg MM. Safety and efficacy of sildenafil citrate in the treatment of male erectile dysfunction. Clin Ther. 1998;20(6):1033-1048. [pmid: 9916601].
Goldstein I. Oral phentolamine: an alpha-1, alpha-2 adrenergic antagonist for the treatment of erectile dysfunction. [Review][9 refs]. Int J Impot Res 2000;12Suppl-80.
Gontero P, Fontana F, Zitella A, et al. A prospective evaluation of efficacy and compliance with a multistep treatment approach for erectile dysfunction in patients after non-nerve sparing radical prostatectomy. BJU Int. 2005;95(3):359-365. [pmid: 15679794].
Gore JL, Swerdloff RS, Rajfer J. Androgen deficiency in the etiology and treatment of erectile dysfunction. Urol Clin North Am. 2005;32(4):457-468. [pmid: 16291037].
Govier FE, McClure RD, Kramer-Levien D. Endocrine screening for sexual dysfunction using free testosterone determinations. Br J Urol. 1996;156(2 Pt 1):405-408.
Graul A, Castaner J. Phentolamine Mesilate. Treatment of erectile dysfunction. Drugs of the Future. 1998;23(7):725-728.
Graul AI. Latest findings on the diagnosis and treatment of erectile dysfunction. Drug News Perspect. 1996;9(9):572-575.
Gray PB, Singh AB, Woodhouse LJ, et al. Dose-dependent effects of testosterone on sexual function, mood, and visuospatial cognition in older men. Journal of Clinical Endocrinology & Metabolism. 2005;90(7):3838-3846. [pmid: 15827094].
Greco E, Balbi PP, Virag R. Self intra-cavernous injections as a successful treatment in pure neurogenic impotence. Riv Neurol. 1991;61(1):35-38. [pmid: 1857921].
Green HJ, Pakenham KI, Headley BC, et al. Coping and health-related quality of life in men with prostate cancer randomly assigned to hormonal medication or close monitoring. Psychooncology. 2002;11(5):401-414. [pmid: 12228873].
Green JSA, Holden STR, Ingram P, et al. An investigation of erectile dysfunction in Gwent, Wales. BJU Int. 2001;88(6):551-553. [pmid: 11678749].
Greenstein A, Plymate SR, Katz PG. Visually stimulated erection in castrated men. Br J Urol. 1995;153(3:Pt 1):t-2.
Gresser U, Gleiter CH. Erectile dysfunction: comparison of efficacy and side effects of the PDE-5 inhibitors sildenafil, vardenafil and tadalafil—review of the literature. [Review] [92 refs]. Eur J Med Res. 2002;7(10):435-446. [pmid: 12435622].
Gross AJ, Sauerwein DH, Kutzenberger J, et al. Penile prostheses in paraplegic men. Br J Urol. 1996;78(2):262-264. [pmid: 8813925].
Grover JK, Vats V, Ajeeta. Sildenafil (Viagra(TM)). Medico-Legal Update. 1998;3(12):67-78.
Grugni G, Carani C, Maestroni G, et al. Melatonin levels in psychogenic impotence. Hormone & Metabolic Research. 1994;26(9):440-441. [pmid: 7835831].
Grunwald JE, Jacob SS, Siu K, et al. Acute effects of sildenafil citrate (Viagra) on intraocular pressure in open-angle glaucoma. Am J Ophthalmol. 2001;132(6):872-874. [pmid: 11730651].
Gryglewska B, Grodzicki T. Betaxolol in elderly patients in primary care. New Medicine. 2003;6(4):108-111.
Guay AT, Sabharwal P, Varma S, et al. Delayed diagnosis of psychological erectile dysfunction because of the presence of macroprolactinemia. Journal of Clinical Endocrinology & Metabolism. 1996;81(7):2512-2514. [pmid: 8675569].
Guay DRP. Geriatric pharmacotherapy updates. American Journal Geriatric Pharmacotherapy. 2004;2(1):81-87.
Guirguis W R, Maytom M C, Orr M et al. SILDENAFIL FOR ERECTILE DYSFUNCTION - A ONE-YEAR STUDY. 151st Annual Meeting of the American Psychiatric Association 1998;Toronto, Ontario, Canada. 30th May-4th June. 1998. Issue No. 63, 1998.
Guo YL, Zhu JC, Pan TM, et al. Efficacy and safety of oral sildenafil in the treatment of erectile dysfunction. Chinese Journal of Urology. 2001;22(7):389-394.
Gupta N, Sawlani K K, Tripathi A K. Appropriate use of sildenafil citrate in male erectile dysfunction.[see comment]. [Review] [52 refs]. J Assoc Physicians India. 2001;49:889-896. [pmid: 11837756].
Gupta S, Salimpour P, Saenz de, et al. A possible mechanism for alteration of human erectile function by digoxin: inhibition of corpus cavernosum sodium/potassium adenosine triphosphatase activity. Br J Urol. 1998;159(5):1529-1536.
Hackett GI. The treatment of patients with diabetes. Int J STD AIDS. 1996;7(Suppl 3):24-26. [pmid: 8876378].
Haensel SM, Klem TM, Hop WC, et al. Fluoxetine and premature ejaculation: a double-blind, crossover, placebo-controlled study. J Clin Psychopharmacol. 1998;18(1):72-77. [pmid: 9472846].
Haensel SM, Rowland DL, Kallan KT. Clomipramine and sexual function in men with premature ejaculation and controls. Br J Urol. 1996;156(4):1310-1315.
Hamed S, Mohamed K, El-taher A, et al. The sexual and reproductive health in men with generalized epilepsy: A multidisciplinary evaluation. Int J Impot Res. 2006;18(3):287-295. [pmid: 16254569].
Hammadeh MY, Philp T. Transurethral electrovaporization of the prostate (TUVP) is effective, safe and durable. [Review] [28 refs]. Prostate Cancer & Prostatic Diseases. 2003;6(2):121-126. [pmid: 12806369].
Hammadeh MY, Madaan S, Hines J, et al. 5-year outcome of a prospective randomized trial to compare transurethral electrovaporization of the prostate and standard transurethral resection. Urology. 2003;61(6):1166-1171. [pmid: 12809891].
Hanash KA. Comparative results of goal oriented therapy for erectile dysfunction. Br J Urol. 1997;157(6):2135-2138.
Harman SM. Testosterone, Sexuality, and Erectile Function in Aging Men. J Androl. 2003;24(6 SUPPL.):S42-S45. [pmid: 14581494].
Hartmann Uwe, Langer Dieter. Combination of psychosexual therapy and intrapenile injections in the treatment of erectile dysfunctions: Rationale and predictors of outcome. J Sex Educ Ther. 1993;19(1):1-12.
Harwood PJ, Grotz M, Eardley I, et al. Erectile dysfunction after fracture of the pelvis. Journal of Bone & Joint Surgery - British Volume. 2005;87(3):281-290.
Haslam MT. A trial of idazoxan and yohimbine in erectile dysfunction. Sex Marital Ther. 1992;7(3):261-266.
Hatzichristou D G. Sildenafil citrate: lessons learned from 3 years of clinical experience. [Review][60 refs]. Int J Impot Res 2002;14Suppl-52.
Hatzichristou D G. Current treatment and future perspectives for erectile dysfunction. [Review][85 refs]. Int J Impot Res 1998;10Suppl-13.
Hatzimouratidis K, Hatzichristou D. Testosterone and erectile function: an unresolved enigma. Eur Urol. 2007;52(1):26-28. [pmid: 17379397].
Hatzimouratidis K, Hatzichristou D. Phosphodiesterase Type 5 Inhibitors: The Day After. Eur Urol. 2007;51(1):75-89. [pmid: 16949200].
Hatzimouratidis K, Hatzichristou DG. A comparative review of the options for treatment of erectile dysfunction: Which treatment for which patient?. Drugs. 2005;65(12):1621-1650. [pmid: 16060698].
Hawton Keith, Catalan Jose, Fagg Joan. Sex therapy for erectile dysfunction: Characteristics of couples, treatment outcome, and prognostic factors. Arch Sex Behav. 1992;21(2):161-175. [pmid: 1580787].
Hazell P. Review of new compounds available in Australia for the treatment of attention-deficit hyperactivity disorder. Australasian Psychiatry. 2004;12(4):369-375. [pmid: 15715810].
He XQ, Hong BF, Wang XX, et al. Evaluation of efficacy and safety of oral sildenafil citrate therapy for men with erectile dysfunction. Pharmaceutical Journal of Chinese Peoples Liberation Army. 2002;18(4):205-208.
Heaton J. New classification system for erectile dysfunction therapies. J Androl. 1998;19(4):399-404. [pmid: 9733141].
Heaton JP. Key issues from the clinical trials of apomorphine SL. World J Urol. 2001;19(1):25-31. [pmid: 11289567].
Heaton JPW, Altwein JE. The role of apomorphine SL in the treatment of male erectile dysfunction. BJU International - Supplement. 2001;88(3):36-38.
Heaton JPW, Wagner Porst, Eid Wyllie. Apomorphine: An update of clinical trial results. Int J Impot Res. 2000;12(SUPPL. 4):S67-S73. [pmid: 11035390].
Heaton JP, Dean J, Sleep DJ. Sequential administration enhances the effect of apomorphine SL in men with erectile dysfunction. Int J Impot Res. 2002;14(1):61-64. [pmid: 11896482].
Hellstrom WJG, Kendirci M. Type 5 Phosphodiesterase Inhibitors: Curing Erectile Dysfunction. Eur Urol. 2006;49(6):942-945. [pmid: 16563607].
Hellstrom WJ, Overstreet JW, Yu A, et al. Tadalafil has no detrimental effect on human spermatogenesis or reproductive hormones.[see comment]. Br J Urol. 2003;170(3):887-891.
Hellstrom Wayne JG, Egan Robert A, McGee Hall T, et al. “Visual field defect and intracerebral hemorrhage associated with use of vardenafil (Levitra)”: Comment and Reply. [References]. Neurology. 2006;66(2):293-294. [pmid: 16434684].
Herrmann HC, Chang G, Klugherz BD, et al. Hemodynamic effects of sildenafil in men with severe coronary artery disease.[see comment]. N Engl J Med. 2000;342(22):1622-1626. [pmid: 10833207].
Hirshkowitz M, Moore CA, O'Connor S, et al. Androgen and sleep-related erections. J Psychosom Res. 1997;42(6):541-546. [pmid: 9226601].
Hirst JF, Watson JP. Referrals aged 60+ to an inner-city psychosexual dysfunction clinic. Sexual & Marital Therapy. 1996;11(2):131-146.
Hofner K, Claes H, De Reijke TM, et al. Tamsulosin 0.4 mg once daily: effect on sexual function in patients with lower urinary tract symptoms suggestive of benign prostatic obstruction. Eur Urol. 1999;36(4):335-341. [pmid: 10473995].
Hollander JB, Gonzalez J, Norman T. Patient satisfaction with pharmacologic erection program. Urology. 1992;39(5):439-441. [pmid: 1580034].
Holt S. Natural approaches to promote sexual function: Part 1: Viagra versus a natural approach. Alternative & Complementary Therapies. 1999;5(4):204-208.
Holtkamp M, Weissinger F, Meierkord H. Erectile dysfunction with topiramate. Epilepsia. 2005;46(1):166-167. [pmid: 15660786].
Hong B, Ji YH, Hong JH, et al. A double-blind crossover study evaluating the efficacy of korean red ginseng in patients with erectile dysfunction: a preliminary report.[see comment]. Br J Urol. 2002;168(5):2070-2073.
Hopps CV, Mulhall JP. Novel agents for sexual dysfunction. BJU Int. 2003;92(6):534-538. [pmid: 14511028].
Horita H, Sato Y, Adachi H, et al. Effects of levodopa on nocturnal penile tumescence: a preliminary study. J Androl. 1998;19(5):619-624. [pmid: 9796623].
Howes OD, Wheeler MJ, Pilowsky LS, et al. Sexual function and gonadal hormones in patients taking antipsychotic treatment for schizophrenia or schizoaffective disorder. Hillside J Clin Psychiatry. 2007;68(3):361-367.
Howes Oliver D, Smith Shubulade, Aitchison Kathy JE. Comments on “Prolactin Levels and Erectile Function in Patients Treated With Risperidone.” [References]. J Clin Psychopharmacol. 2005;25(4):393-394. [pmid: 16012288].
Huang ST, Hsieh ML. Different hemodynamic responses by color Doppler ultrasonography studies between sildenafil non-responders and responders. Asian J Androl. 2007;9(1):129-133. [pmid: 17187164].
Huang WJ, Chen KK, Chang LS. Correlation between voiding and erectile function in patients with symptomatic benign prostatic hyperplasia. Journal of the Chinese Medical Association: JCMA. 2005;68(4):178-182. [pmid: 15850068].
Hubler J, Szanto A, Konyves K. Methylene blue as a means of treatment for priapism caused by intracavernous injection to combat erectile dysfunction. International Urology & Nephrology. 2003;35(4):519-521. [pmid: 15198160].
Hultling C. Partners' perceptions of the efficacy of sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Clin Pract 1999;Supplement.102–108.
Hummel S, Paisley S, Morgan A, et al. Clinical and cost-effectiveness of new and emerging technologies for early localised prostate cancer: A systematic review. Health Technol Assess. 2003;7(33):157p.
Hunter R H, Joy C B, Kennedy E et al. Risperidone versus typical antipsychotic medication for schizophrenia.[update of Cochrane Database Syst Rev. 2000;(2):CD000440; PMID: 10796543]. [Review][105 refs]. Cochrane Database Syst Rev 2003;(2):CD000440
Hyer SL, Duckworth K, Jones C. Managing erectile disorders in diabetes: The one stop andrology clinic. Practical Diabetes International. 1998;15(8):225-226.
Isidori AM, Giannetta E, Gianfrilli D, et al. Effects of testosterone on sexual function in men: results of a meta-analysis. Clin Endocrinol (Oxf). 2005;63(4):381-394. [pmid: 16181230].
Israilov S, Baniel J, Shmueli J, et al. Treatment program for erectile dysfunction in patients with cardiovascular diseases. Am J Cardiol. 2004;93(6):689-693. [pmid: 15019870].
Jackson G. Erectile dysfunction and cardiovascular disease.[see comment]. [Review] [46 refs]. Int J Clin Pract. 1999;53(5):363-368. [pmid: 10695101].
Jackson G. Treatment of erectile dysfunction in patients with cardiovascular disease: Guide to drug selection. Drugs. 2004;64(14):1533-1545. [pmid: 15233591].
Jackson G. Vardenafil - PDE5 inhibitor number 3. Int J Clin Pract. 2004;58(3):229. [pmid: 15117087].
Jackson G. PDE5 inhibitors: Looking beyond ED. Int J Clin Pract. 2003;57(3):159-160. [pmid: 12723713].
Jackson G. Sildenafil (Viagra): New data, new confidence in treating erectile dysfunction in the cardiovascular patient. Int J Clin Pract. 2002;56(2):75. [pmid: 11926708].
Jackson G. Phosphodiesterase 5 inhibition: Effects on the coronary vasculature. Int J Clin Pract. 2001;55(3):183-188. [pmid: 11351772].
Jackson G. The metabolic syndrome and erectile dysfunction: multiple vascular risk factors and hypogonadism. Eur Urol. 2006;50(3):426-427. [pmid: 16644094].
Jackson G, Montorsi P, Cheitlin MD. Cardiovascular safety of sildenafil citrate (Viagra): an updated perspective. [Review] [52 refs]. Urology. 2006;68(3 Suppl):47-60. [pmid: 17011375].
Jackson G, Sweeney M, Osterloh IH. Sildenafil citrate (Viagra(TM)): A cardiovascular overview. British Journal of Cardiology. 1999;6(6):325-334.
Jain P, Rademaker AW, McVary KT. Testosterone supplementation for erectile dysfunction: results of a meta-analysis. Br J Urol. 2000;164(2):371-375.
James J S. Frequent urination, leg cramps, leg weakness, erection difficulties: HIV myelopathy amino acid study. AIDS Treat News 2000;(344):3–4.
Jani AB. The effectiveness of combining hormone therapy and radiotherapy in the treatment of prostate cancer. Expert Opin Pharmacother. 2004;5(12):2469-2477. [pmid: 15571465].
Jani AB, Kao J, Heimann R, et al. Hormone therapy and radiotherapy for early prostate cancer: A utility-adjusted number needed to treat (NNT) analysis. Int J Radiat Oncol Biol Phys. 2005;61(3):687-694. [pmid: 15708246].
Jarow JP, Nana-Sinkam P, Sabbagh M, et al. Outcome analysis of goal directed therapy for impotence. Br J Urol. 1996;155(5):1609-1612.
Jeong SJ, Park K, Moon JD, et al. Bicycle saddle shape affects penile blood flow. Int J Impot Res. 2002;14(6):513-517. [pmid: 12494288].
Jiann BP, Yu CC, Su CC. Impact of introduction of sildenafil on other treatment modalities for erectile dysfunction: A study of nationwide and local hospital sales. Int J Impot Res. 2004;16(6):527-530. [pmid: 15229626].
Jordan GH. What's new in urology. J Am Coll Surg. 2003;197(3):444-457. [pmid: 12946801].
Kadioglu A, Erdogru T, Tellaloglu S. Evaluation of penile arteries in papaverine-induced erection with color Doppler ultrasonography. Arch Esp Urol. 1995;48(6):654-658. [pmid: 7661649].
Kamel HK, Morley JE. The management of erectile dysfunction. Reproductive Medicine Review. 2001;9(1):35-47.
Kang BJ, Lee SJ, Kim MD, et al. A placebo-controlled, double-blind trial of Ginkgo biloba for antidepressant-induced sexual dysfunction. Hum Psychopharmacol. 2002;17(6):279-284. [pmid: 12404672].
Kaplan SA, Meehan AG, Shah A. The age related decrease in testosterone is significantly exacerbated in obese men with the metabolic syndrome. What are the implications for the relatively high incidence of erectile dysfunction observed in these men?. Br J Urol. 2006;176(4 Pt 1):1524-1527.
Karlawish JH, Casarett D. Sildenafil for diabetic men with erectile dysfunction.[comment]. JAMA. 1999;282(10):940-941. [pmid: 10485673].
Kassouf W, Carrier S. A comparison of the International Index of Erectile Function and erectile dysfunction studies. BJU Int. 2003;91(7):667-669. [pmid: 12699481].
Kaufman JM, Hatzichristou DG, Mulhall JP, et al. Impotence and chronic renal failure: a study of the hemodynamic pathophysiology. Br J Urol. 1994;151(3):612-618.
Keijzers GB. Aviptadil (Senatek). [Review] [36 refs]. Curr Opin Investig Drugs. 2001;2(4):545-549.
Keles I, Aydin G, Orkun S, et al. Two clinical problems in elderly men: osteoporosis and erectile dysfunction. Arch Androl. 2005;51(3):177-184. [pmid: 16025856].
Kell P. Cardiovascular safety of sildenafil. Int J STD AIDS. 2002;13(7):439-443. [pmid: 12171661].
Keoghane SR, Sullivan ME, Miller MAW. The aetiology, pathogenesis and management of priapism. BJU Int. 2002;90(2):149-154. [pmid: 12081756].
Kerfoot WW, Park HY, Schwartz LB, et al. Characterization of calcium channel blocker induced smooth muscle relaxation using a model of isolated corpus cavernosum. Br J Urol. 1993;150(1):249-252.
Kernohan AF, McIntyre M, Hughes DM, et al. An oral yohimbine/L-arginine combination (NMI 861) for the treatment of male erectile dysfunction: a pharmacokinetic, pharmacodynamic and interaction study with intravenous nitroglycerine in healthy male subjects. Br J Clin Pharmacol. 2005;59(1):85-93. [pmid: 15606445].
Khalaf IM, Levinson IP. Erectile dysfunction in the Africa/Middle East Region: Epidemiology and experience with sildenafil citrate (Viagra). Int J Impot Res. 2003;15(SUPPL. 1):S1-S2. [pmid: 12825101].
Khan LA. Sildenafil citrate (Viagra). JK Pract. 2001;8(1):52-53.
Khan MA, Raistrick M, Mikhailidis DP, et al. MUSE: clinical experience. Current Medical Research & Opinion. 2002;18(2):64-67. [pmid: 12017211].
Kilic S, Ergin H, Baydinc YC. Venlafaxine extended release for the treatment of patients with premature ejaculation: a pilot, single-blind, placebo-controlled, fixed-dose crossover study on short-term administration of an antidepressant drug. Int J Androl. 2005;28(1):47-52. [pmid: 15679621].
Kilic S, Salih M, Anafarta K, et al. Adenosine: a new agent in the diagnosis of impotence. Int J Impot Res. 1994;6(4):191-198. [pmid: 7795719].
Kim JM, Joh YD, Huh JD, et al. Doppler sonography of the penile cavernosal artery: comparison of intraurethral instillation and intracorporeal injection of prostaglandin E1. J Clin Ultrasound. 2001;29(5):273-278. [pmid: 11486321].
Kim NN. Phosphodiesterase type 5 inhibitors: A biochemical and clinical correlation survey. Int J Impot Res. 2003;15(SUPPL. 5):S13-S19. [pmid: 14551572].
Kim NN, Dhir V, Azadzoi KM, et al. Pilot study of the endothelin-A receptor selective antagonist BMS-193884 for the treatment of erectile dysfunction. J Androl. 2001;23(1):76-83. [pmid: 11780926].
Kim SC, Seo KK, Lee SK, et al. Comparison of the synergistic effects of tamsulosin versus phentolamine on penile erection: In vitro and in vivo studies. Urol Res. 1999;27(6):437-444. [pmid: 10651132].
Kim SC, Seo KK, Park BD, et al. Risk factors for an early increase in dose of vasoactive agents for intracavernous pharmacotherapy. Urol Int. 2000;65(4):204-207. [pmid: 11112870].
Kimoto Y, Sakamoto S, Fujikawa K, et al. Up-titration of vardena fi l dose from 10 mg to 20 mg improved erectile function in men with spinal cord injury. Int J Urol. 2006;13(11):1428-1433. [pmid: 17083398].
Kirby RS. Report from London. Prostate Cancer & Prostatic Diseases. 2005;8(4):299. [pmid: 16319940].
Kirby RS, Andersen M, Gratzke P, et al. A combined analysis of double-blind trials of the efficacy and tolerability of doxazosin-gastrointestinal therapeutic system, doxazosin standard and placebo in patients with benign prostatic hyperplasia. BJU Int. 2001;87(3):192-200. [pmid: 11167641].
Kirby RS, O'Leary MP, Carson C. Efficacy of extended-release doxazosin and doxazosin standard in patients with concomitant benign prostatic hyperplasia and sexual dysfunction. BJU Int. 2005;95(1):103-109. [pmid: 15638905].
Kiriakova N, Kiriakov A, Schneider E, et al. Therapeutic effect of essential phospholipids on functional sexual disorders in males. Journal of the European Academy of Dermatology & Venereology. 1998;11(2):191-193. [pmid: 9784056].
Kleinberg DL, Davis JM, De Coster R, et al. Prolactin levels and adverse events in patients treated with risperidone.[see comment]. J Clin Psychopharmacol. 1999;19(1):57-61. [pmid: 9934944].
Kley HK, Stremmel W, Kley JB, et al. Testosterone treatment of men with idiopathic hemochromatosis. Clin Investig. 1992;70(7):566-572.
Kloner RA. Cardiovascular risk and sildenafil. [Review] [27 refs]. Am J Cardiol. 2000;86(2A):57F-61F.
Kloner RA, Zusman RM. Cardiovascular effects of sildenafil citrate and recommendations for its use. [Review] [21 refs]. Am J Cardiol. 1999;84(5B):11N-17N.
Kloner RA, Brindis RG, Cheitlin MD, et al. Roundtable discussion: Tadalafil study group. Am J Cardiol. 2003;92(9 SUPPL. 1):58M-65M.
Kloner RA, Hutter AM, Emmick JT, et al. Time course of the interaction between tadalafil and nitrates.[see comment]. J Am Coll Cardiol. 2003;42(10):1855-1860. [pmid: 14642699].
Kloner RA, Jackson G, Emmick JT, et al. Interaction between the phosphodiesterase 5 inhibitor, tadalafil and 2 alpha-blockers, doxazosin and tamsulosin in healthy normotensive men. Br J Urol. 2004;172(5:Pt 1):t-40.
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil in patients on common antihypertensive therapies. [Review] [5 refs]. Am J Cardiol. 2003;92(9A):47M-57M. [pmid: 12842244].
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil. [Review] [12 refs]. Am J Cardiol. 2003;92(9A):37M-46M.
Klotz T, Mathers MJ, Braun M, et al. Effectiveness of oral L-arginine in first-line treatment of erectile dysfunction in a controlled crossover study. Urol Int. 1999;63(4):220-223. [pmid: 10743698].
Knegtering R, Castelein S, Bous H, et al. A Randomized Open-Label Study of the Impact of Quetiapine Versus Risperidone on Sexual Functioning. J Clin Psychopharmacol. 2004;24(1):56-61. [pmid: 14709948].
Knispel HH. Penile venous surgery in impotence: results in highly selected cases. Urol Int. 1991;47(3):144-148. [pmid: 1771702].
Knoll LD, Benson RC, Bilhartz DL, et al. A randomized crossover study using yohimbine and isoxsuprine versus pentoxifylline in the management of vasculogenic impotence. Br J Urol. 1996;155(1):144-146.
Kobayashi T, Okuno H, Nishiyama H, et al. Adult-onset idiopathic hypogonadotropic hypogonadism presented with erectile and ejaculatory disorder. Int J Urol. 2002;9(10):604-606. [pmid: 12445243].
Kramer-Levien D J. Papaverine—the medical implant. AUAA J 1987;7(4):13-Jun.
Krause W, Mueller U, Mazur A. Measurement of steroid levels in saliva in a population-based survey of lifestyle, medical conditions, marriage, sex life and hormone status in aging men: A feasibility study. Aging Male. 2002;5(4):203-215. [pmid: 12630067].
Kriston L, Harms A, Berner MM. A meta-regression analysis of treatment effect modifiers in trials with flexible-dose oral sildenafil for erectile dysfunction in broad-spectrum populations. Int J Impot Res. 2006;18(6):559-565. [pmid: 16688210].
Kromann-Andersen B. Intracavernosal pharmacotherapy with injection pen. Lancet. 1988;1(85756):54-59. [pmid: 2891913].
Kuba R, Pohanka M, Zakopcan J, et al. Sexual dysfunctions and blood hormonal profile in men with focal epilepsy. Epilepsia. 2006;47(12):2135-2140. [pmid: 17201714].
Kukreja RC, Ockaili R, Salloum F, et al. Cardioprotection with phosphodiesterase-5 inhibition - A novel preconditioning strategy. Journal of Molecular & Cellular Cardiology. 2004;36(2):165-173. [pmid: 14871543].
Kunelius P, Hakkinen J, Lukkarinen O. Is high-dose yohimbine hydrochloride effective in the treatment of mixed-type impotence? A prospective, randomized, controlled double-blind crossover study. Urology. 1997;49(3):441-444. [pmid: 9123711].
Kupecz D. Alprostadil for the treatment of erectile dysfunction. J Am Acad Nurse Pract. 1996;21(5):143-145.
Kupelian V, Shabsigh R, Travison TG, et al. Is there a relationship between sex hormones and erectile dysfunction? Results from the Massachusetts Male Aging Study. Br J Urol. 2006;176(6 Pt 1):2584-2588.
Kvistborg A, Halse J, Bakke S, et al. Long-term treatment of macroprolactinomas with CV 205–502. Acta Endocrinol (Copenh). 1993;128(4):301-307. [pmid: 8098891].
La Pera G, Franco Giannotti C, Taggi F, et al. Prevalence of sexual disorders in those young males who later become drug abusers. J Sex Marital Ther. 2003;29(2):149-156. [pmid: 12623766].
La Vignera S, Calogero AE, Cannizzaro MA, et al. Erectile vascular dysfunction and analysis of the risk factors related to it. Clinical experience. Minerva Endocrinol. 2007;32(1):17-21. [pmid: 17353863].
Labbate Lawrence A. “Sex and serotonin reuptake inhibitor antidepressants”: Erratum. Psychiatr Ann. 1999;29(12):683.
Labbate Lawrence A, Croft Harry A, Oleshansky Marvin AE. Antidepressant-Related Erectile Dysfunction: Management via Avoidance, Switching Antidepressants, Antidotes, and Adaptation. [References]. Hillside J Clin Psychiatry. 2003;64(Suppl 10):11-19.
Labbate Lawrence A, Grimes Jamie, Hines Alan, et al. Sexual dysfunction induced by serotonin reuptake antidepressants. J Sex Marital Ther. 1998;24(1):3-12. [pmid: 9509375].
Lamberg L. New drug for erectile dysfunction boon for many, ‘viagravation’ for some. J Am Med Assoc. 1998;280(10):867-869.
Larson TR. Current treatment options for benign prostatic hyperplasia and their impact on sexual function. Urology. 2003;61(4):692-698. [pmid: 12670545].
Lasaponara F, Paradiso M, Milan MG, et al. Erectile dysfunction after kidney transplantation: our 22 years of experience.[see comment]. Transplant Proc. 2004;36(3):502-504. [pmid: 15110572].
Laties A, Sharlip I. Ocular safety in patients using sildenafil citrate therapy for erectile dysfunction. [Review] [81 refs]. Br J Sex Med. 2006;3(1):12-27.
Laties AM, Zrenner E. Viagra (sildenafil citrate) and ophthalmology. Progress in Retinal & Eye Research. 2002;21(5):485-506. [pmid: 12207947].
Laties A M, Fraunfelder F T, Flach A J et al. Ocular safety of Viagra, (sildenafil citrate). Trans Am Ophthalmol Soc 1999;97(pp 115–128):-128.
Latini DM, Penson DF, Lubeck DP, et al. Longitudinal differences in disease specific quality of life in men with erectile dysfunction: Results from the exploratory comprehensive evaluation of erectile dysfunction study. Br J Urol. 2003;169(4):1437-1442.
Laumann Edward O, West Suzanne, Glasser Dale, et al. Prevalence and Correlates of Erectile Dysfunction by Race and Ethnicity Among Men Aged 40 or Older in the United States: From the Male Attitudes Regarding Sexual Health Survey. [References]. Br J Sex Med. 2007;4(1):57-65.
Lawless C, Cree J. Oral medications in the management of erectile dysfunction. [Review] [15 refs]. J Am Board Fam Pract. 1998;11(4):307-314. [pmid: 9719353].
Lawless C, Force RW. Sildenafil for erectile dysfunction. J Fam Pract. 1998;47(2):97-98. [pmid: 9722794].
Lawrence IG, Price DE, Howlett TA, et al. Correcting impotence in the male dialysis patient: experience with testosterone replacement and vacuum tumescence therapy. Am J Kidney Dis. 1998;31(2):313-319. [pmid: 9469503].
Lea AP, Bryson HM, Balfour JA. Intracavernous alprostadil. A review of its pharmacodynamic and pharmacokinetic properties and therapeutic potential in erectile dysfunction. [Review] [123 refs]. Drugs Aging. 1996;8(1):56-74. [pmid: 8785470].
Lebret T, Herve JM, Gorny P, et al. Efficacy and safety of a novel combination of L-arginine glutamate and yohimbine hydrochloride: a new oral therapy for erectile dysfunction. Eur Urol. 2002;41(6):608-613. [pmid: 12074777].
Lee WR. The role of androgen deprivation therapy combined with prostate brachytherapy. [Review] [31 refs]. Urology. 2002;60(3:Suppl 1):Suppl-44.
Lehmann K, Casella R, Blochlinger A, et al. Reasons for discontinuing intracavernous injection therapy with prostaglandin E1 (alprostadil). Urology. 1999;53(2):397-400. [pmid: 9933062].
Lehmann K, John H, Kacl G, et al. Variable response to intracavernous prostaglandin E1 testing for erectile dysfunction. Urology. 1999;54(3):539-543. [pmid: 10475368].
Lenze EJ, Karp JF, Mulsant BH, et al. Somatic symptoms in late-life anxiety: Treatment issues. Journal of Geriatric Psychiatry & Neurology. 2005;18(2):89-96. [pmid: 15911937].
Lenzi A. The role of the medical andrologist in the assisted reproduction era. J Endocrinol Invest. 2003;26(3):268-273. [pmid: 12809180].
Leslie SJ, Atkins G, Oliver JJ, et al. No adverse hemodynamic interaction between sildenafil and red wine. Clinical Pharmacology & Therapeutics. 2004;76(4):365-370. [pmid: 15470336].
Levien T, Baker DE. Lepirudin and sildenafil citrate. Hosp Pharm. 1998;33(12):1524-1552.
Levine SB. A slightly different idea. Arch Sex Behav. 2005;34(1):38-39. [pmid: 16092025].
Levy MM. Benefits being missed [5]. Can Pharm J. 2005;274(7334):109.
Lewis RL, Sadovsky R, Eardley I, et al. The efficacy of tadalafil in clinical populations. Br J Sex Med. 2005;2(4):517-531.
Lexchin J. New drugs with novel therapeutic characteristics. Have they been subject to randomized controlled trials?. Can Fam Physician. 2002;48(SEPT.):1487-1492. [pmid: 12371307].
Li JY, Li XY, Li M, et al. Decline of serum levels of free testosterone in aging healthy Chinese men. Aging Male. 2005;8(34):203-206. [pmid: 16390747].
Licht MR. Use of oral sildenafil (Viagra) in the treatment of erectile dysfunction. [Review] [13 refs]. Compr Ther. 1999;25(2):90-94. [pmid: 10091013].
Lim PHC, Man KL, Foo CN, et al. Clinical efficacy and safety of sildenafil citrate (Viagra) in a multi-racial population in Singapore: A retrospective study of 1520 patients. Int J Urol. 2002;9(6):308-315. [pmid: 12110094].
Lim P H C, Moorthy P, Benton K G F. The clinical safety of Viagra. Ann N Y Acad Sci 2002;962(pp 378–388):-388.
Limoge JP, Olins E, Henderson D, et al. Minimally invasive therapies in the treatment of erectile dysfunction in anticoagulated cases: a study of satisfaction and safety. Br J Urol. 1996;155(4):1276-1279.
Lin CS, Xin ZC, Lin G, et al. Phosphodiesterases as therapeutic targets. Urology. 2003;61(4):685-691. [pmid: 12670544].
Lincoln TM. Cyclic GMP and phosphodiesterase 5 inhibitor therapies: What's on the horizon. Mol Pharmacol. 2004;66(1):11-13. [pmid: 15213291].
Lindsey I. What is the incidence of sexual dysfunction in males following rectal excision for benign and malignant diseases?. National Research Register 2000;2000.
Linet OI, Neff LL. Intracavernous prostaglandin E1 in erectile dysfunction. Clin Investig. 1994;72(2):139-149.
Linnebur SA. Pharmacotherapy update: What's new about old medications. Annals of Long Term Care. 2004;12(9):34-44.
Lipshultz LI. Injection therapy for erectile dysfunction. N Engl J Med. 1996;334(14):913-914. [pmid: 8596577].
Lipshultz LI, Kim ED. Treatment of erectile dysfunction in men with diabetes. J Am Med Assoc. 1999;281(5):465-466.
Llisterri JL, Lozano Vidal JV, Aznar Vicente J, et al. Sexual dysfunction in hypertensive patients treated with losartan. Am J Med Sci. 2001;321(5):336-341. [pmid: 11370797].
Long RL, Sherman LS, Lombardi TJ. A goal-oriented, cost-effective approach to the diagnosis and treatment of 24 male erectile dysfunction. [Review] [24 refs]. J Ky Med Assoc. 1995;93(11):500-508. [pmid: 8778212].
Loudon Julia B. Potential confusion between erectile dysfunction and premature ejaculation: An evaluation of men presenting with erectile difficulty at a sex therapy clinic. Sexual & Marital Therapy. 1998;13(4):397-403.
Lu J, SJ Fan J, Zhu J, et al. The prospective and randomized control study of Viagra combined with Andriol in the treatment of ED in the aging male. Chinese Journal of Andrology. 2003;17(3):194-196.
Lue TF. Erectile dysfunction. N Engl J Med. 2000;342(24):1802-1813. [pmid: 10853004].
Lue TF. Impotence after radical pelvic surgery: physiology and management. [Review] [56 refs]. Urol Int. 1991;46(3):259-265. [pmid: 1926639].
Lukkarinen O, Tonttila P, Hellstrom P, et al. Non-prosthetic surgery in the treatment of erectile dysfunction. A retrospective study of 45 impotent patients in the University of Oulu. Scandinavian Journal of Urology & Nephrology. 1998;32(1):42-46. [pmid: 9561573].
Lunenfeld B. Androgen therapy in the aging male. [Review] [110 refs]. World J Urol. 2003;21(5):292-305. [pmid: 14576959].
Maan Z, Arya M, Shergill I, et al. Peyronie's disease: An update of the medical management. Expert Opin Pharmacother. 2004;5(4):799-805. [pmid: 15102564].
Maas R, Schwedhelm E, Albsmeier J, et al. The pathophysiology of erectile dysfunction related to endothelial dysfunction and mediators of vascular function. Vasc Med. 2002;7(3):213-225. [pmid: 12553745].
Mahmud A, Hennessy M, Feely J. Effect of sildenafil on blood pressure and arterial wave reflection in treated hypertensive men. J Hum Hypertens. 2001;15(10):707-713. [pmid: 11607801].
Maier U, Koinig G. Andrological findings in young patients under long-term antidepressive therapy with clomipramine. Psychopharmacology (Berl). 1994;116(3):357-359. [pmid: 7892427].
Mak R, De Backer G, Kornitzer M, et al. Prevalence and correlates of erectile dysfunction in a population-based study in Belgium. Eur Urol. 2002;41(2):132-138. [pmid: 12074399].
Manasia P, Pomerol J, Ribe N, et al. Comparison of the efficacy and safety of 90 mg versus 20 mg fluoxetine in the treatment of premature ejaculation. Br J Urol. 2003;170(1):164-165.
Manecke RG, Mulhall JP. Medical treatment of erectile dysfunction. [Review] [69 refs]. Ann Med. 1999;31(6):388-398. [pmid: 10680853].
Manganiello V. International Journal of Impotence Research: Editorial commentary. Int J Impot Res. 2004;16(SUPPL. 1):S1-S3. [pmid: 15224126].
Mann K, Klingler T, Noe S, et al. Effects of yohimbine on sexual experiences and nocturnal penile tumescence and rigidity in erectile dysfunction. Arch Sex Behav. 1996;25(1):1-16. [pmid: 8714425].
Mann RD. Introduction - Tadalafil. Journal of Drug Evaluation. 2004;2(8):223.
Mann RD. Executive summary sildenafil citrate (Viagra). Journal of Drug Evaluation. 2003;1(7):221-223.
Manning M, Junemann KP, Scheepe JR, et al. Long-term followup and selection criteria for penile revascularization in erectile failure.[see comment]. Br J Urol. 1998;160(5):1680-1684.
Marberger M, Roehrborn CG, Marks LS, et al. Relationship among serum testosterone, sexual function, and response to treatment in men receiving dutasteride for benign prostatic hyperplasia. Journal of Clinical Endocrinology & Metabolism. 2006;91(4):1323-1328. [pmid: 16434455].
Margel D, Tal R, Livne PM, et al. Predictors of erectile function improvement in obstructive sleep apnea patients with long-term CPAP treatment. Int J Impot Res. 2005;17(2):186-190. [pmid: 15510189].
Mark SD, Keane TE, Vandemark RM, et al. Impotence following pelvic fracture urethral injury: incidence, aetiology and management. Br J Urol. 1995;75(1):62-64. [pmid: 7850299].
Markou S, Perimenis P, Gyftopoulos K, et al. Vardenafil (Levitra) for erectile dysfunction: a systematic review and meta-analysis of clinical trial reports. Int J Impot Res. 2004;16(6):470-478. [pmid: 15229625].
Marquer C, Bressolle F. Moxisylyte: A review of its pharmacodynamic and pharmacokinetic properties, and its therapeutic use in impotence. Fundam Clin Pharmacol. 1998;12(4):377-387. [pmid: 9711459].
Martin DJ, Badwan K, Parker M, et al. Transdermal application of verapamil gel to the penile shaft fails to infiltrate the tunica albuginea. Br J Urol. 2002;168(6):2483-2485.
Martins FE, Reis JP. Visual erotic stimulation test for initial screening of psychogenic erectile dysfunction: a reliable noninvasive alternative?. Br J Urol. 1997;157(1):134-139.
Masand PS, Ashton AK, Gupta S, et al. Sustained-release bupropion for selective serotonin reuptake inhibitor-induced sexual dysfunction: a randomized, double-blind, placebo-controlled, parallel-group study.[see comment]. Am J Psychiatry. 2001;158(5):805-807. [pmid: 11329407].
Matthew AG, Goldman A, Trachtenberg J, et al. Sexual dysfunction after radical prostatectomy: Prevalence, treatments, restricted use of treatments and distress. Br J Urol. 2005;174(6):2105-2110.
Maytom MC, Derry FA, Dinsmore WW, et al. A two-part pilot study of sildenafil (VIAGRA) in men with erectile dysfunction caused by spinal cord injury. Spinal Cord. 1999;37(2):110-116. [pmid: 10065749].
McCarthy Barry W. Relapse prevention strategies and techniques with erectile dysfunction. J Sex Marital Ther. 2001;27(1):1-8. [pmid: 11224950].
McClellan KJ, Goa KL. Transdermal testosterone. [Review] [17 refs]. Drugs. 1998;55(2):253-258. [pmid: 9506244].
McClure RD. Endocrine evaluation and therapy of erectile dysfunction. [Review] [77 refs]. Urol Clin North Am. 1988;15(1):53-64. [pmid: 3278476].
McConnell JD, Roehrborn CG, Bautista OM, et al. The Long-Term Effect of Doxazosin, Finasteride, and Combination Therapy on the Clinical Progression of Benign Prostatic Hyperplasia. N Engl J Med. 2003;349(25):2387-2398. [pmid: 14681504].
McCullough AR, Barada JH, Fawzy A, et al. Achieving treatment optimization with sildenafil citrate (Viagra) in patients with erectile dysfunction. Urology. 2002;60(2 Suppl 2):28-38. [pmid: 12414331].
McKinlay J B. The worldwide prevalence and epidemiology of erectile dysfunction. [Review][17 refs]. Int J Impot Res 2000;12Suppl-S11.
McMahon C. Comparison of erectile responses to differing doses of prostaglandin PGE1 in an attempt to standardise pharmacological diagnosis of impotence. Journal of Assisted Reproduction & Genetics 1992;9265A
McMahon CG. Nonsurgical treatment of cavernosal venous leakage. Urology. 1997;49(1):97-100. [pmid: 9000193].
McMahon CG. Treatment of Erectile Dysfunction with Chronic Dosing of Tadalafil. Eur Urol. 2006;50(2):215-217. [pmid: 16844542].
McMahon CG. Priapism associated with concurrent use of phosphodiesterase inhibitor drugs and intracavernous injection therapy. Int J Impot Res. 2003;15(5):383-384. [pmid: 14562142].
McMahon CG, Stuckey BGA, Andersen M, et al. Efficacy of sildenafil citrate (viagra) in men with premature ejaculation. Br J Sex Med. 2005;2(3):368-375.
Mealy NE. NBI-69733. Drugs of the Future. 2004;29(6):642.
Mealy NE. GPI-1485. Drugs of the Future. 2004;29(6):640.
Mealy NE. EMR-62203. Drugs of the Future. 2004;29(6):639.
Mealy NE. Dasantafil. Drugs of the Future. 2004;29(6):633.
Mealy NE. DA-8159. Drugs of the Future. 2004;29(6):631.
Mealy NE. Avanafil. Drugs of the Future. 2004;29(6):628-629.
Mealy NE. Alprostadil cream. Drugs of the Future. 2004;29(6):626-627.
Mealy NE, Bayes M. PT-141. Drugs of the Future. 2004;29(11):1177.
Mealy NE, Bayes M. ABT-724. Drugs of the Future. 2005;30(9):935.
Mehdiyev T V. Intracavernous injection probe of vasoactive preparations in the diagnosis of erectile dysfunctions in patients with diabetes mellitus. Azerbaidzhanskii Meditsinskii Zhurnal 2002;(pp 17–19):-19.
Meinhardt W, Kropman RF, Vermeij P, et al. The influence of medication on erectile function. Int J Impot Res. 1997;9(1):17-26. [pmid: 9138055].
Melman A, Bar-Chama N, McCullough A, et al. The first human trial for gene transfer therapy for the treatment of erectile dysfunction: preliminary results. Eur Urol. 2005;48(2):314-318. [pmid: 15964135].
Mendelson WB, Gujavarty K, Slintak C, et al. Reported sexual dysfunction in obstructive sleep apnea patients. Ann Clin Psychiatry. 1990;2(2):93-101.
Merrick GS, Wallner KE, Butler WM. Minimizing prostate brachytherapy-related morbidity. Urology. 2003;62(5):786-792. [pmid: 14624895].
Metawea B, El-Nashar AR, Gad-Allah A, et al. Intracavernous papaverine/phentolamine-induced priapism can be accurately predicted with color Doppler ultrasonography. Urology. 2005;66(4):858-860. [pmid: 16230153].
Meyhoff HH, Rosenkilde P, Bodker A. Non-invasive management of impotence with transcutaneous nitroglycerin. Br J Urol. 1992;69(1):88-90. [pmid: 1737261].
Migliari R, Muscas G, Usai E. Effect of Casodex on sleep-related erections in patients with advanced prostate cancer. Br J Urol. 1992;148(2 I):338-341.
Mikhail N. Efficacy and safety of sildenafil in patients with congestive heart failure [7]. Arch Intern Med. 2004;164(18):2067-2068. [pmid: 15477449].
Millard RJ, Stricker PD, Lynch WJ, et al. Risks of self-injection therapy for impotence. Med J Aust. 1996;165(2):117-118. [pmid: 8692055].
Miller DC, Wei JT, Dunn RL, et al. Use of medications or devices for erectile dysfunction among long-term prostate cancer treatment survivors: potential influence of sexual motivation and/or indifference. Urology. 2006;68(1):166-171. [pmid: 16844457].
Miller N, Smolkin ME, Bissonette E, et al. Undetectable prostate specific antigen at 6–12 months: a new marker for early success in hormonally treated patients after prostate brachytherapy. Cancer. 2005;103(12):2499-2506. [pmid: 15852361].
Mills RD, Sethia KK. Maximisation of the erectile response in the investigation of impotence. Int J Impot Res. 1999;11(1):29-32. [pmid: 10098951].
Mills TM, Lewis RW. The role of androgens in the erectile response: A 1999 perspective. Mol Urol. 1999;3(2):75-80. [pmid: 10851308].
Milman HA, Arnold SB, Rivera-Miranda G, et al. Neurologic, psychological, and aggressive disturbances with sildenafil. Ann Pharmacother. 2002;36(78):1129-1134. [pmid: 12086542].
Mirone VG, Stief CG. Efficacy of apomorphine SL in erectile dysfunction.[erratum appears in BJU Int 2002 Jan;89(1):140]. [Review] [11 refs]. BJU Int. 2001;88(Suppl 3):25-29. [pmid: 11578276].
Mittleman MA, Glasser DB, Orazem J. Clinical trials of sildenafil citrate (Viagra) demonstrate no increase in risk of myocardial infarction and cardiovascular death compared with placebo. Int J Clin Pract. 2003;57(7):597-600. [pmid: 14529061].
Mittleman MM, Rosen RC. Evaluating clinical trial design results and analysis of drug treatments for erectile dysfunction. Int J Impot Res. 2003;15(4):x-xiii.
Miwa Y, Kaneda T, Yokoyama O. Correlation between the Aging Males' Symptoms Scale and sex steroids, gonadotropins, dehydroepiandrosterone sulfate, and growth hormone levels in ambulatory men. Br J Sex Med. 2006;3(4):723-726.
Mohr BA, Bhasin S, Link CL, et al. The effect of changes in adiposity on testosterone levels in older men: longitudinal results from the Massachusetts Male Aging Study. Eur J Endocrinol. 2006;155(3):443-452. [pmid: 16914599].
Montejo A L, Llorca G, Izquierdo J A et al. Incidence of sexual dysfunction associated with antidepressant agents: a prospective multicenter study of 1022 outpatients. Spanish Working Group for the Study of Psychotropic-Related Sexual Dysfunction.[see comment]. Hillside J Clin Psychiatry 2001;62Suppl-21.
Montejo-Gonzalez AL, Llorca G, Izquierdo JA, et al. SSRI-induced sexual dysfunction: fluoxetine, paroxetine, sertraline, and fluvoxamine in a prospective, multicenter, and descriptive clinical study of 344 patients. Journal of Sex and Marital Therapy. 1997;23(3):176-194. [pmid: 9292833].
Montorsi F. A multicenter, randomized, double-blind, crossover study to evaluate patient preference between tadalafil and sildenafil: Editorial comment. Eur Urol. 2004;45(4):508-509.
Montorsi F, Althof SE. Partner responses to sildenafil citrate (Viagra) treatment of erectile dysfunction. Urology. 2004;63(4):762-767. [pmid: 15072897].
Montorsi F, Burnett AL. Erectile dysfunction after radical prostatectomy. BJU Int. 2004;93(1):1-2. [pmid: 14678354].
Montorsi F, Briganti A, Salonia A, et al. Current and Future Strategies for Preventing and Managing Erectile Dysfunction Following Radical Prostatectomy. Eur Urol. 2004;45(2):123-133. [pmid: 14733995].
Montorsi F, Briganti A, Salonia A, et al. Can Phosphodiesterase Type 5 Inhibitors Cure Erectile Dysfunction?. Eur Urol. 2006;49(6):979-986. [pmid: 16431013].
Montorsi F, Guazzoni G, Bocciardi A, et al. Improved minimally-invasive assessment of penile haemodynamics: the combination of colour Doppler sonography and injection-stimulation test. Int J Impot Res. 1995;7(1):33-40. [pmid: 7670591].
Montorsi F, Perani D, Anchisi D, et al. Brain activation patterns during video sexual stimulation following the administration of apomorphine: results of a placebo-controlled study. Eur Urol. 2003;43(4):405-411. [pmid: 12667722].
Montorsi F, Salonia A, Briganti A, et al. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol. 2005;47(5):612-621. [pmid: 15826752].
Montorsi F, Strambi LF, Guazzoni G, et al. Effect of yohimbine-trazodone on psychogenic impotence: a randomized, double-blind, placebo-controlled study. Urology. 1994;44(5):732-736. [pmid: 7974947].
Moore R A, Edwards J E, McQuay H J. Sildenafil (Viagra) for male erectile dysfunction: a meta-analysis of clinical trial reports. BMC Urol. 2002;26
Morales A. Men's aging and sexual disorders: An update on diagnosis and treatment. Rev Endocr Metab Disord. 2005;6(2):85-92. [pmid: 15843879].
Morales A, Gingell C, Collins M, et al. Clinical safety of oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):69-73. [pmid: 9647940].
Morales Alvaro, Condra Michael, Heaton Jeremy P, et al. Impotence: Organic factors and management approach. Sexual & Marital Therapy. 1991;6(2):97-106.
Moreira ED, Lbo CF, Diament A, et al. Incidence of erectile dysfunction in men 40 to 69 years old: results from a population-based cohort study in Brazil. Urology. 2003;61(2):431-436. [pmid: 12597962].
Moreira E D, Lisboa Lobo C F, Villa M et al. Prevalence and correlates of erectile dysfunction in Salvador, northeastern Brazil: a population-based study. Int J Impot Res 2002;14Suppl-9.
Morley John E, Kaiser Fran E. Aging and sexuality. Vellas, Bruno (Ed); Albarede, J 1992;-L(Ed):1992–165.
Mulhall JP. Deciphering erectile dysfunction drug trials. [Review] [35 refs]. Br J Urol. 2003;170(2 Pt 1):353-358.
Mulhall JP. Sublingual apomorphine for the treatment of erectile dysfunction. [Review] [22 refs]. Expert Opin Investig Drugs. 2002;11(2):295-302.
Mulhall JP, bdel-Moneim A, Abobakr R, et al. Improving the accuracy of vascular testing in impotent men: correcting hemodynamic alterations using a vasoactive medication re-dosing schedule. Br J Urol. 2001;166(3):923-926.
Mulhall JP, Daller M, Traish AM, et al. Intracavernosal forskolin: Role in management of vasculogenic impotence resistant to standard 3-agent pharmacotherapy. Br J Urol. 1997;158(5):1752-1759.
Mulhall JP, Levine LA, Junemann KP. Erection hardness: a unifying factor for defining response in the treatment of erectile dysfunction. [Review] [37 refs]. Urology. 2006;68(3 Suppl):17-25. [pmid: 17011372].
Mulligan T, Schmitt B. Testosterone for erectile failure. J Gen Intern Med. 1993;8(9):517-521. [pmid: 8410427].
Mulligan T, Frick MF, Zuraw QC, et al. Prevalence of hypogonadism in males aged at least 45 years: the HIM study. Int J Clin Pract. 2006;60(7):762-769. [pmid: 16846397].
Muneer A, Ralph DJ, Minhas S. Sildenafil citrate (Viagra). Journal of Drug Evaluation. 2003;1(7):225-246.
Munoz M, Bancroft J, Beard M. Evaluating the effects of an alpha-2 adrenoceptor antagonist on erectile function in the human male. 2. The erectile response to erotic stimuli in men with erectile dysfunction, in relation to age and in comparison with normal volunteers. Psychopharmacology (Berl). 1994;115(4):471-477. [pmid: 7871091].
Munoz M, Bancroft J, Turner M. Evaluating the effects of an alpha-2 adrenoceptor antagonist on erectile function in the human male. 1. The erectile response to erotic stimuli in volunteers. Psychopharmacology (Berl). 1994;115(4):463-470. [pmid: 7871090].
Murphy AM, O'Leary M. Failure of the Ambicor inflatable penile prosthesis to deflate. Int J Impot Res. 2005;17(3):291-292. [pmid: 15605073].
Murphy JC, Srinivas S, Terris MK. Flutamide administration at 500 mg daily has similar effects on serum testosterone to 750 mg daily. J Androl. 2004;25(4):630-634. [pmid: 15223852].
Nagai A, Kusumi N, Tsuboi H, et al. Intracavernous injection of prostaglandin E1 is effective in patients with erectile dysfunction not responding to phosphodiseterase 5 inhibitors. Acta Med Okayama. 2005;59(6):279-280. [pmid: 16418771].
Nakata M, Takashima S, Kaminou T, et al. Embolotherapy for venous impotence: use of ethanol. Journal of Vascular & Interventional Radiology. 2000;11(8):1053-1057. [pmid: 10997470].
Nakonezny PA, Byerly MJ, Rush AJ. The relationship between serum prolactin level and sexual functioning among male outpatients with schizophrenia or schizoaffective disorder: A randomized double-blind trial of risperidone vs. quetiapine. J Sex Marital Ther. 2007;33(3):203-216. [pmid: 17454518].
Nalesnik JG, Jones L, Kraus SR. Group B streptococcal septicemia following intracavernous injection therapy for erectile dysfunction in diabetes. Br J Urol. 2004;172(1):151-152.
Nandwani R, Gourlay Y. Possible interaction between sildenafil and HIV combination therapy [1]. Lancet. 1999;353(9155):840. [pmid: 10459981].
Narayan P, Trachtenberg J, Lepor H, et al. A dose-response study of the effect of flutamide on benign prostatic hyperplasia: results of a multicenter study. Urology. 1996;47(4):497-504. [pmid: 8638357].
Neese Leah E, Schover Leslie R, Klein Eric A, et al. Finding help for sexual problems after prostate cancer treatment: A phone survey of men's and women's perspectives. [References]. Psychooncology. 2003;12(5):463-473. [pmid: 12833559].
Nehra A, Blute ML, Barrett DM, et al. Rationale for combination therapy of intraurethral prostaglandin E(1) and sildenafil in the salvage of erectile dysfunction patients desiring noninvasive therapy. Int J Impot Res. 2002;14(Suppl 1):38-42. [pmid: 11896476].
Neumeyer K, Kirkpatrick P. Tadalafil and vardenafil. Nat Rev Genet. 2004;3(4):295-296.
Nicolosi A, Moreira ED, Shirai M, et al. Epidemiology of erectile dysfunction in four countries: cross-national study of the prevalence and correlates of erectile dysfunction. Urology. 2003;61(1):201-206. [pmid: 12559296].
Nieschlag E, Swerdloff R, Behre HM, et al. Investigation, treatment and monitoring of late-onset hypogonadism in males: ISA, ISSAM, and EAU recommendations. Int J Androl. 2005;28(3):125-127. [pmid: 15910536].
Nurnberg H G, Hensley P L. Sildenafil citrate for the management of antidepressant-associated erectile dysfunction. Hillside J Clin Psychiatry 2003;64Suppl-5.
Nurnberg HG, Gelenberg A, Hargreave TB, et al. Efficacy of sildenafil citrate for the treatment of erectile dysfunction in men taking serotonin reuptake inhibitors. Am J Psychiatry. 2001;158(11):1926-1928. [pmid: 11691705].
Nurnberg HG, Seidman SN, Gelenberg AJ, et al. Depression, antidepressant therapies, and erectile dysfunction: clinical trials of sildenafil citrate (Viagra) in treated and untreated patients with depression. Urology. 2002;60(2 Suppl 2):58-66. [pmid: 12414334].
Nurnberg H, George. Erectile Dysfunction and Comorbid Depression: Prevalence, Treatment Strategies, and Associated Medical Conditions. [References]. Hillside J Clin Psychiatry. 2003;64(Suppl10):3-4.
Nurnberg H, George Hensley, Paula L, et al. Sildenafil in the treatment of sexual dysfunction induced by selective serotonin reuptake inhibitors: An overview. [References]. CNS Drugs. 2000;13(5):321-335.
O'Sullivan JD. Apomorphine as an alternative to sildenafil in Parkinson's disease. [References]. Journal of Neurology, Neurosurgery & Psychiatry. 2002;72(5):681.
O'Sullivan JD, Hughes AJ. Apomorphine-induced penile erections in Parkinson's disease. Mov Disord. 1998;13(3):536-539. [pmid: 9613749].
Oefelein MG. Time to normalization of serum testosterone after 3-month luteinizing hormone-releasing hormone agonist administered in the neoadjuvant setting: implications for dosing schedule and neoadjuvant study consideration.[see comment]. Br J Urol. 1998;160(5):1685-1688.
Ohebshalom M, Mulhall JP. Transdermal and topical pharmacotherapy for male sexual dysfunction. Expert Opinion on Drug Delivery. 2005;2(1):115-120. [pmid: 16296739].
Ojumu A, Dobs AS. Is Hypogonadism a Risk Factor for Sexual Dysfunction?. J Androl. 2003;24(6 SUPPL.):S46-S51. [pmid: 14581495].
Onu PE. Depot medroxyprogesterone in the management of benign prostatic hyperplasia. Eur Urol. 1995;28(3):229-235. [pmid: 8536777].
Opsomer RJ, Wese FX, De Groote P, et al. The external vacuum device in the management of erectile dysfunction. Acta Urol Belg. 1997;65(4):13-16. [pmid: 9497591].
Ormrod D, Easthope SE, Figgitt DP. Vardenafil.[erratum appears in Drugs Aging 2002;19(11):886]. [Review] [30 refs]. Drugs Aging. 2002;19(3):217-227. [pmid: 12027779].
Osterloh IH, Riley A. Clinical update on sildenafil citrate. [Review] [58 refs]. Br J Clin Pharmacol. 2002;53(3):219-223. [pmid: 11874383].
Osterloh I H, Collins M, Wicker P et al. Sildenafil citrate (VIAGRA): overall safety profile in 18 double-blind, placebo controlled, clinical trials. [Review][0 refs]. Int J Clin Pract 1999;Supplement.102–105.
Owens J. Seeking selectivity. Nat Rev Genet. 2005;4(2):106.
Ozbek E, Yurekli M, Soylu A, et al. The role of adrenomedullin in varicocele and impotence. BJU Int. 2000;86(6):694-698. [pmid: 11069379].
Ozdel O, Oguzhanoglu A, Oguzhanoglu NK, et al. A follow-up study of male sexual disorders: The neurophysiological assessments, anxiety-depression levels, and response to fluoxetine treatment [10]. J Clin Psychopharmacol. 2004;24(4):461-463. [pmid: 15232347].
Padma-Nathan H, Eardley I, Kloner RA, et al. A 4-year update on the safety of sildenafil citrate (Viagra). [Review] [88 refs]. Urology. 2002;60(2:Suppl 2):Suppl-90.
Pagani E, Glina S, Puech-Leao P, et al. Anxiety and high plasma catecholamines do not impair pharmaco-induced erection of psychogenic erectile dysfunctional patients. Int J Impot Res. 2003;15(4):282-286. [pmid: 12934057].
Paice Judith A, Penn Richard D, Ryan Will G. Altered sexual function and decreased testosterone in patients receiving intraspinal opioids. J Pain Symptom Manage. 1994;9(2):126-131. [pmid: 7517429].
Paick JS, Yang JH, Kim SW, et al. Severity of erectile dysfunction in married impotent patients: interrelationship with anthropometry, hormones, metabolic profiles and lifestyle. Int J Urol. 2007;14(1):48-53. [pmid: 17199860].
Paick JS, Yang JH, Kim SW, et al. The role of prolactin levels in the sexual activity of married men with erectile dysfunction. BJU Int. 2006;98(6):1269-1273. [pmid: 17125484].
Paick SH, Meehan A, Lee M, et al. The relationship among lower urinary tract symptoms, prostate specific antigen and erectile dysfunction in men with benign prostatic hyperplasia: results from the proscar long-term efficacy and safety study. Br J Urol. 2005;173(3):903-907.
Palha AP, Gomes FA, Martins AS, et al. [Clinical, multicentric, and open study to evaluate the efficacy of and tolerance to sildenafil in patients with erectile dysfunction]. Acta Med Port. 2002;15(4):249-256. [pmid: 12525018].
Pan CC, Lin JSN, Wong WS. Comparison of effect on erection between vacuum constriction devices and intra-cavernous injection of prostaglandin E1. Asian J Surg. 1997;20(2):162-166.
Papatsoris AG, Deliveliotis C, Singer C, et al. Erectile dysfunction in Parkinson's disease. Urology. 2006;67(3):447-451. [pmid: 16504269].
Parazzini F, Menchini Fabris F, Bortolotti A, et al. Frequency and determinants of erectile dysfunction in Italy. Eur Urol. 2000;37(1):43-49. [pmid: 10671784].
Paris G, Sponsel WE, Sandoval SS, et al. Sildenafil increases ocular perfusion. Int Ophthalmol. 2001;23(46):355-358. [pmid: 11944862].
Parker C. The Scandinavian Prostate Cancer Group Study: The case for conservative management. BJU Int. 2005;96(7):952-953. [pmid: 16225505].
Parsons JK, Marschke P, Maples P, et al. Effect of methylprednisolone on return of sexual function after nerve-sparing radical retropubic prostatectomy. Urology. 2004;64(5):987-990. [pmid: 15533491].
Patankar M. Sildenafil citrate. J Indian Med Assoc 2000;98(12):
Patterson D, Kloner R, Effron M, et al. The effect of tadalafil on the time to exercise-induced myocardial ischaemia in subjects with coronary artery disease. Br J Clin Pharmacol. 2005;60(5):459-468. [pmid: 16236035].
Pegge NC, Twomey AM, Vaughton K, et al. The role of endothelial dysfunction in the pathophysiology of erectile dysfunction in diabetes and in determining response to treatment. Diabet Med. 2006;23(8):873-878. [pmid: 16911625].
Penninga E, Jensen BA, Hansen PB, et al. Anagrelide treatment in 52 patients with chronic myeloproliferative diseases. Clinical & Laboratory Haematology. 2004;26(5):335-340. [pmid: 15485463].
Penson DF, Feng Z, Kuniyuki A, et al. General quality of life 2 years following treatment for prostate cancer: what influences outcomes? Results from the prostate cancer outcomes study.[see comment]. Am J Clin Oncol. 2003;21(6):1147-1154.
Perez Martin A, Skinner Eila C, Meyerowitz Beth EE. Sexuality and intimacy following radical prostatectomy: Patient and partner perspectives. [References]. Health Psychol. 2002;21(3):288-293. [pmid: 12027035].
Perimenis P, Athanasopoulos A, Papathanasopoulos P, et al. Gabapentin in the management of the recurrent, refractory, idiopathic priapism. Int J Impot Res. 2004;16(1):84-85. [pmid: 14963477].
Pescatori ES, Calpista A, Artibani W, et al. Self-injection devices for intracavernosal pharmacotherapy: operational classification and safety considerations. Int J Impot Res. 1996;8(2):53-57. [pmid: 8858390].
Pescatori ES, Silingardi V, Galeazzi GM, et al. Audiovisual sexual stimulation by virtual glasses is effective in inducing complete cavernosal smooth muscle relaxation: a pharmacocavernosometric study. Int J Impot Res. 2000;12(2):83-88. [pmid: 11052633].
Phelps JS, Jain A, Monga M. The PsychoedPlusMed approach to erectile dysfunction treatment: the impact of combining a psychoeducational intervention with sildenafil. J Sex Marital Ther. 2004;30(5):305-314. [pmid: 15672598].
Philipp M, Kohnen R, Benkert O. A comparison study of moclobemide and doxepin in major depression with special reference to effects on sexual dysfunction. Int Clin Psychopharmacol. 1993;7(34):149-153. [pmid: 8468436].
Philipp M, Tiller JWG, Baier D, et al. Comparison of moclobemide with selective serotonin reuptake inhibitors (SSRIs) on sexual function in depressed adults. Eur Neuropsychopharmacol. 2000;10(5):305-314. [pmid: 10974600].
Phillips BG, Kato M, Pesek CA, et al. Sympathetic activation by sildenafil.[see comment]. Circulation. 2000;102(25):3068-3073. [pmid: 11120696].
Pirotte B, de Tullio P, Antoine MH, et al. New insights into the development of ATP-sensitive potassium channel openers. Expert Opinion on Therapeutic Patents. 2005;15(5):497-504.
Pisters LL, von Eschenbach AC, Scott SM, et al. The efficacy and complications of salvage cryotherapy of the prostate. J Urol. 1997;157(3):921-925. [pmid: 9072600].
Pittler M, Ernst E. Trials have shown yohimbine is effective for erectile dysfunction [14]. Br Med J. 1998;317(7156):478. [pmid: 9703549].
Polak K, Wimpissinger B, Berisha F, et al. Effects of sildenafil on retinal blood flow and flicker-induced retinal vasodilatation in healthy subjects. Invest Ophthalmol Vis Sci. 2003;44(11):4872-4876. [pmid: 14578411].
Pollack Mark H, Reiter Stewart, Hammerness Paul. Genitourinary and sexual adverse effects of psychotropic medication. Int J Psychiatry Med. 1992;22(4):305-327. [pmid: 1363418].
Pomara G, Morelli G, Montorsi F, et al. Re: Montorsi F, Salonia A, Briganti A, Barbieri L, Zanni G, Surdi N, Cestari A, Montorsi P, Rigatti P. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol 2005;47:612–21 (multiple letters). Eur Urol. 2005;48(2):345-346. [pmid: 15939526].
Pomerantz JM. Viagra and medical necessity. Drug Benefit Trends. 2002;14(10):33-40.
Pommerville P. Drug treatments for erectile dysfunction: An update. Geriatrics and Aging. 2004;7(6):10-16.
Pommerville P J. From bedside to bed. Recovery of sexual function after prostate cancer. Can Fam Physician 2005;51(JULY):941–943+948.
Porst H. IC351 (tadalafil, Cialis): update on clinical experience. [Review][12 refs]. Int J Impot Res 2002;14Suppl-64.
Porst H. Phosphodiesterase type-5 inhibitors: A critical comparative analysis. Eau Update Series. 2004;2(2):56-63.
Porst HC. Re-dosing of prostaglandin-E1 versus prostaglandin-E1 plus phentolamine in male erectile dysfunction: a dynamic color power Doppler study. Int J Impot Res. 2000;12(2):134-135. [pmid: 11052645].
Porst H, Giuliano F, Glina S, et al. Evaluation of the Efficacy and Safety of Once-a-Day Dosing of Tadalafil 5 mg and 10 mg in the Treatment of Erectile Dysfunction: Results of a Multicenter, Randomized, Double-Blind, Placebo-Controlled Trial. Eur Urol. 2006;50(2):351-359. [pmid: 16766116].
Pouaha J, Martin S, Reichert-Penetrat S, et al. Thalidomide and sexual dysfunction in men.[comment]. Br J Dermatol. 2002;146(6):1112-1113. [pmid: 12072099].
Power-Smith Parsley. Beneficial sexual side-effects from fluoxetine. Br J Psychiatry Suppl 1994;164 Feb 1994, 249–250. http249–250.
Pradeep C, Car N, Metelko Z. Impotence in diabetic men. Diabetol Croat. 1996;25(2):61-68.
Pratt-Ubunama MN, Nishizaka MK, Calhoun DA. Aldosterone antagonism: An emerging strategy for effective blood pressure lowering. Curr Hypertens Rep. 2005;7(3):186-192. [pmid: 15913492].
Preskorn SH. Duloxetine. Journal of Psychiatric Practice. 2004;10(6):375-385. [pmid: 15583519].
Price DE, Cooksey G, Jehu D, et al. The management of impotence in diabetic men by vacuum tumescence therapy. Diabet Med. 1991;8(10):964-967. [pmid: 1838050].
Prins J, Blanker MH, Bohnen AM, et al. Prevalence of erectile dysfunction: A systematic review of population-based studies. Int J Impot Res. 2002;14(6):422-432. [pmid: 12494273].
Priyadarshi S. Oral terbutaline in the management of pharmacologically induced prolonged erection. Int J Impot Res. 2004;16(5):424-426. [pmid: 14999218].
Pryor J. Vardenafil: update on clinical experience. [Review][10 refs]. Int J Impot Res 2002;14Suppl-9.
Pryor JP. Orgasmic and ejaculatory dysfunction. Sexual & Relationship Therapy. 2002;17(1):87-95.
Qian LX, Wu HF, Xu H, et al. Multi-center Evaluation of Efficacy and Safety of Oral Mesylate Phentolamine for the Treatment of Erectile Dysfunction. Int J Androl. 2001;7(5):302-305.
Quinn MJ, Jefferson K, Persad R. Benign prostatic hyperplasia and sexual dysfunction [3] (multiple letters). Lancet. 2003;361(9368):1562. [pmid: 12737897].
Quirk J, Thornton M, Neumeyer K, et al. Cardiology and vascular disorders. Nat Rev Genet. 2004;3(7 SUPPL.):S12-S17.
Radomski SB, Herschorn S, Rangaswamy S. Topical minoxidil in the treatment of male erectile dysfunction. Br J Urol. 1994;151(5):1225-1226.
Ramasubbu R. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Ramasubbu Rajamannar. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Ramasubbu Rajamannar. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Rashid A. The efficacy and safety of PDE5 inhibitors. [Review] [30 refs]. Clin Cornerstone. 2005;7(1):47-56. [pmid: 16156423].
Reffelmann T, Kloner RA. Effects of sildenafil on myocardial infarct size, microvascular function, and acute ischemic left ventricular dilation. Cardiovasc Res. 2003;59(2):441-449. [pmid: 12909327].
Reyes JA, Tan DA, Quimpo JA, et al. The Philippine Male Aging Survey. Aging Male. 2004;7(3):227-235. [pmid: 15669542].
Rhoden EL, Estrada C, Levine L, et al. The value of pituitary magnetic resonance imaging in men with hypogonadism.[see comment]. Br J Urol. 2003;170(3):795-798.
Richardson JD. Intracorporeal injections for the treatment of impotence. Med J Aust. 1991;155(10):688. [pmid: 1943899].
Richter S, Vardi Y, Ringel A, et al. Intracavernous injections: still the gold standard for treatment of erectile dysfunction in elderly men. Int J Impot Res. 2001;13(3):172-175. [pmid: 11525316].
Riley Alan. Oral treatments for erectile dysfunction. Int J STD AIDS. 1996;7(Suppl 3):16-18. [pmid: 8876375].
Rizvi K, Hampson JP, Harvey JN. Do lipid-lowering drugs cause erectile dysfunction? A systematic review.[see comment]. [Review] [35 refs]. Fam Pract. 2002;19(1):95-98. [pmid: 11818357].
Roach M, Winter K, Michalski JM, et al. Penile bulb dose and impotence after three-dimensional conformal radiotherapy for prostate cancer on RTOG 9406: findings from a prospective, multi-institutional, phase I/II dose-escalation study. Int J Radiat Oncol Biol Phys. 2004;60(5):1351-1356. [pmid: 15590164].
Rodrigues M, Granegger S, O'Grady J, et al. Accumulation of platelets as a key mechanism of human erection. A scintigraphic study in patients with erectile dysfunction receiving intracavernous injection of PGE1, papaverine/phentolamine. Advances in Experimental Medicine & Biology. 1997;43:379-82.
Roizenblatt S, Guilleminault C, Poyares D, et al. A double-blind, placebo-controlled, crossover study of sildenafil in obstructive sleep apnea. Arch Intern Med. 2006;166(16):1763-1767. [pmid: 16983056].
Rojewski MT, Korper S, Schrezenmeier H. Arsenic trioxide therapy in acute promyelocytic leukemia and beyond: From bench to bedside. Leuk Lymphoma. 2004;45(12):2387-2401. [pmid: 15621751].
Rosano GM, Marazzi G, Patrizi R, et al. Comparison of trimetazidine plus sildenafil to chronic nitrates in the control of myocardial ischemia during sexual activity in patients with coronary artery disease. Am J Cardiol. 2005;95(3):327-331. [pmid: 15670539].
Rosas-Vargas H, Coral-Vazquez RM, Tapia R, et al. Glu298Asp endothelial nitric oxide synthase polymorphism is a risk factor for erectile dysfunction in the Mexican Mestizo population. J Androl. 2004;25(5):728-732. [pmid: 15292102].
Rose VL. Sildenafil in the treatment of erectile dysfunction. Am Fam Physician. 1998;58(1):268.
Rosen RC, Kostis JB. Overview of phosphodiesterase 5 inhibition in erectile dysfunction. Am J Cardiol. 2003;92(9 SUPPL. 1):9M-18M.
Rosen RC, Lane RM, Menza M. Effects of SSRIs on sexual function: a critical review.[see comment]. [Review] [255 refs]. J Clin Psychopharmacol. 1999;19(1):67-85. [pmid: 9934946].
Rosen RC, Shabsigh R, Kuritzky L, et al. The efficacy of tadalafil in improving sexual satisfaction and overall satisfaction in men with mild, moderate, and severe erectile dysfunction: A retrospective pooled analysis of data from randomized, placebo-controlled clinical trials. Current Medical Research & Opinion. 2005;21(11):1701-1709. [pmid: 16307689].
Rosen Raymond C. Erectile dysfunction: The medicalization of male sexuality. Clin Psychol Rev. 1996;16(6):497-519.
Rosen Raymond C, Leiblum Sandra R. Treatment of male erectile disorder: Current options and dilemmas. Sexual & Marital Therapy. 1993;8(1):5-8.
Rosen Raymond C, Leiblum Sandra, Risa. Erectile disorders: An overview of historical trends and clinical perspectives. Rosen, Raymond C (Ed); Leiblum, Sandra Risa (Ed) 1992;(1992):378
Rosenthal BD, May NR, Metro MJ, et al. Adjunctive use of AndroGel (testosterone gel) with sildenafil to treat erectile dysfunction in men with acquired androgen deficiency syndrome after failure using sildenafil alone. Urology. 2006;67(3):571-574. [pmid: 16527581].
Rowland DL, Greenleaf WJ, Dorfman LJ, et al. Aging and sexual function in men. Arch Sex Behav. 1993;22(6):545-557. [pmid: 8285844].
Rowland DL, Kallan K, Slob AK. Yohimbine, erectile capacity, and sexual response in men. Arch Sex Behav. 1997;26(1):49-62. [pmid: 9015579].
Rudkin L, Taylor M J, Hawton K. Strategies for managing sexual dysfunction induced by antidepressant medication. [Review][61 refs]. Cochrane Database Syst Rev 2004;(4):CD003382
Ruof J, Graf-Morgenstern M, Mnller MJ. Quality of life in patients with erection difficulties: Evaluation of a German version of the “Quality of life measure for men with erection difficulties” (QoL-Med). Aktuel Urol. 2001;32(1):21-26.
Ryder RE, Close CF, Moriarty KT, et al. Impotence in diabetes: aetiology, implications for treatment and preferred vacuum device. Diabet Med. 1992;9(10):893-898. [pmid: 1478032].
Saad F, Grahl AS, Aversa A, et al. Effects of testosterone on erectile function: implications for the therapy of erectile dysfunction. BJU Int. 2007;99(5):988-992. [pmid: 17309554].
Saad F, Hoesl CE, Oettel M, et al. Dehydroepiandrosterone treatment in the aging male - What should the urologist know?. Eur Urol. 2005;48(5):724-733. [pmid: 16137821].
Sadock Virginia A. A sexually compulsive male with erectile dysfunction treated with Viagra: Discussion. Journal of Sex Education & Therapy. 1998;23(4):275-277.
Safarinejad MR. Prevalence and risk factors for erectile dysfunction in a population-based study in Iran. Int J Impot Res. 2003;15(4):246-252. [pmid: 12934051].
Sairam K, Kulinskaya E, Boustead GB, et al. Prevalence of undiagnosed prostate cancer in men with erectile dysfunction. BJU Int. 2002;89(3):261-263. [pmid: 11856107].
Sak SC, Eardley I. What is the relationship between benign prostatic hyperplasia and sexual function?. Sexual & Relationship Therapy. 2004;19(4):431-443.
Sakamoto H, Shimada M, Yoshida H. Hemodynamic evaluation of the penile arterial system in patients with erectile dysfunction using power doppler imaging. Urology. 2002;60(3):480-484. [pmid: 12350490].
Saks Bonnie R. A sexually compulsive male with erectile dysfunction treated with Viagra: Case report. Journal of Sex Education & Therapy. 1998;23(4):271-274.
Salonia A, Barbieri L, Chen J, et al. Comparison of the effect of sildenafil and apomorphine SL on nocturnal erections in healthy volunteers: a placebo-controlled study. Eur Urol. 2005;47(4):524-529. [pmid: 15774253].
Salonia A, Maga T, Colombo R, et al. A prospective study comparing paroxetine alone versus paroxetine plus sildenafil in patients with premature ejaculation. Br J Urol. 2002;168(6):2486-2489.
Salonia A, Rigatti P, Montorsi F. Sildenafil in erectile dysfunction: a critical review. Curr.Med Res Opin. 2003;19(4):241-262. [pmid: 12841917].
Salonia Andrea, Briganti Alberto, Montorsi Piero, et al. Safety and tolerability of oral erectile dysfunction treatments in the elderly. [References]. Drugs and Aging. 2005;22(4):323-338. [pmid: 15839721].
Samarasinghe Y, Rivas-Toro H. HEART UK 18th annual medical and scientific meeting: From diabetes to mixed hyperlipidaemias. British Journal of Cardiology. 2004;11(5):364-365.
Sathe RS, Komisaruk BR, Ladas AK, et al. Naltrexone-induced augmentation of sexual response in men. Arch Med Res. 2001;32(3):221-226. [pmid: 11395188].
Sato Y, Horita H, Adachi H, et al. Effect of oral administration of prostaglandin E1 on erectile dysfunction. Br J Urol. 1997;80(5):772-775. [pmid: 9393301].
Sato Y, Suzuki N, Adachi H, et al. Evaluation of the alleviative action of neurotropin for penile pain associated with intracavernous injection of prostaglandin E1 assessed using the visual analogue scale. Int J Impot Res. 1998;10(1):1-3. [pmid: 9542683].
Savoca G, Silvestre G, Belgrano E. Intracavernosal injection therapy and surgical therapy in diabetic patients with erectile dysfunction. [Review] [26 refs]. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):53-57.
Scalvini T, Martini P R, Obici L et al. Infertility and Hypergonadotropic Hypogonadism as First Evidence of Hereditary Apolipoprotein A-I Amyloidosis. Br J Urol 2007;
Schiavi Raul C, Schanzer Harry, Sozio Giampaolo, et al. Erectile function and penile blood pressure in diabetes mellitus. J Sex Marital Ther. 1994;20(2):119-124. [pmid: 8035468].
Schimmer AD, Ali V, Stewart AK, et al. Male sexual function after autologous blood or marrow transplantation. Biology of Blood & Marrow Transplantation. 2001;7(5):279-283. [pmid: 11400950].
Scholz M, Strum S. Re: Recovery of spontaneous erectile function after nerve-sparing radical retropubic prostatectomy with and without early intracavernous injections of alprostadil: results of a prospective, randomized trial.[comment]. Br J Urol. 1999;161(6):1914-1915.
Schouman M, Lacroix P, Amer M. Suppression of prostaglandin E1-induced pain by dilution of the drug with lidocaine before intracavernous injection. Br J Urol. 1992;148(4):1266.
Schrader S, Mills A, Scheperle M, et al. Improvement in sexual functioning and satisfaction in nonresponders to testosterone gel: clinical effectiveness in hypogonadal, HIV-positive males. Clin Cornerstone. 2005;7(Suppl 4):S26-S31. [pmid: 16651205].
Schroder FH, Whelan P, De Reijke TM, et al. Metastatic prostate cancer treated by flutamide versus cyproterone acetate. Final analysis of the “European Organization for Research and Treatment of Cancer” (EORTC) Protocol 30892. Eur Urol. 2004;45(4):457-464. [pmid: 15041109].
Schultheiss D, Stief CG. Physiology and pathophysiology of erection: Consequences for present medical therapy of erectile dysfunction. Andrologia. 1999;31(SUPPL. 1):59-64. [pmid: 10643521].
Schwartz EJ, Wong P, Graydon RJ. Sildenafil preserves intracorporeal smooth muscle after radical retropubic prostatectomy. Br J Urol. 2004;171(2 I):771-774.
Seftel A. Male and female sexual function and dysfunction; andrology. Br J Urol. 2005;174(6):2297-2300.
Seftel A. Effect of lifestyle changes on erectile dysfunction in obese men. A randomized controlled trial. Br J Urol. 2005;173(2):544-545.
Seftel AD. From aspiration to achievement: Assessment and noninvasive treatment of erectile dysfunction in aging men. J Am Geriatr Soc. 2005;53(1):119-130. [pmid: 15667388].
Seftel AD. Male and female sexual function and dysfunction; andrology. Br J Urol. 2005;174(4 I):1364-1366.
Segraves RT. Pharmacological enhancement of human sexual behavior. Journal of Sex Education & Therapy. 1991;17(4):283-289.
Segraves R, Taylor. Two additional uses for sildenafil in psychiatric patients. [References]. J Sex Marital Ther. 1999;25(4):265-266. [pmid: 10546163].
Segraves Robert, Taylor Segraves, Kathleen Blindt, et al. Sexual function in patients taking bupropion sustained release. Hillside J Clin Psychiatry. 1995;56(8):374.
Seidman Stuart N. Exploring the relationship between depression and erectile dysfunction in aging men. Hillside J Clin Psychiatry. 2002;63(Suppl5):5-12.
Setter SM, Iltz JL, Fincham JE, et al. Phosphodiesterase 5 inhibitors for erectile dysfunction. [Review] [75 refs]. Ann Pharmacother. 2005;39(78):1286-1295. [pmid: 15941818].
Seyam RM, Albakry A, Ghobish A, et al. Prevalence of erectile dysfunction and its correlates in Egypt: a community-based study. Int J Impot Res. 2003;15(4):237-245. [pmid: 12934050].
Shabbir M, Mikhailidis DM, Morgan RJ. Erectile dysfunction: an underdiagnosed condition associated with multiple risk factors.[comment]. Current Medical Research & Opinion. 2004;20(5):603-606. [pmid: 15140326].
Shabbir M, Shah JS, Kirby RS. Cardiac failure and benign prostatic hyperplasia: Management of common comorbidities. BJU Int. 2005;95(3):278-280. [pmid: 15679777].
Shabsigh R. Testosterone therapy in erectile dysfunction. [Review] [34 refs]. Aging Male. 2004;7(4):312-318. [pmid: 15799127].
Shabsigh R. Testosterone therapy in erectile dysfunction and hypogonadism. Br J Sex Med. 2005;2(6):785-792.
Shabsigh R. Hypogonadism and erectile dysfunction: The role for testosterone therapy. Int J Impot Res. 2003;15(SUPPL. 4):S9-S13. [pmid: 12934045].
Shabsigh R, Katz M, Yan G, et al. Cardiovascular issues in hypogonadism and testosterone therapy. [Review] [44 refs]. Am J Cardiol. 2005;96(12B):67M-72M. [pmid: 15979436].
Shakir SAW, Wilton LV, Boshier A, et al. Cardiovascular events in users of sildenafil: Results from first phase of prescription event monitoring in England. Br Med J. 2001;322(7287):651-652. [pmid: 11250850].
Shamloul R. Management of honeymoon impotence. Br J Sex Med. 2006;3(2):361-366.
Shamloul R, El-Dakhly M, Ghanem H, et al. Intracavernous chlorpromazine versus phentolamine: A double-blind clinical comparative study. Br J Sex Med. 2004;1(3):310-313.
Shamloul R, Ghanem HM, Salem A, et al. The value of penile duplex in the prediction of intracavernous drug-induced priapism. Int J Impot Res. 2004;16(1):78-79. [pmid: 14961063].
Shamsa A, Motavalli SM, Aghdam B. Erectile function in end-stage renal disease before and after renal transplantation. Transplant Proc. 2005;37(7):3087-3089. [pmid: 16213314].
Sharlip ID. Editorial comment. International Braz J Urol. 2005;31(4):354-355.
Sharlip ID. Can self-injection therapy cure impotence?. [Review] [7 refs]. Advances in Experimental Medicine & Biology. 1997;43:383-86.
Shimon I, Lubina A, Gorfine M, et al. Feedback inhibition of gonadotropins by testosterone in men with hypogonadotropic hypogonadism: comparison to the intact pituitary-testicular axis in primary hypogonadism. J Androl. 2006;27(3):358-364. [pmid: 16474013].
Siegel RL, Dubin NH, Andrade JR. Sildenafil citrate and sperm function [3] (multiple letters). American Journal of Obstetrics & Gynecology. 2001;184(4):777-778. [pmid: 11262489].
Sighinolfi MC, de Stefani S, Mofferdin A, et al. Intracavernous prostaglandin E1 infusion in diabetes with associated ischemic necrosis of the glans penis. Br J Urol. 2004;171(6 I):2380.
Silvestri A, Galetta P, Cerquetani E, et al. Report of erectile dysfunction after therapy with beta-blockers is related to patient knowledge of side effects and is reversed by placebo.[see comment]. Eur Heart J. 2003;24(21):1928-1932. [pmid: 14585251].
Singer Carlos, Weiner William J, Sanchez-Ramos J, et al. Sexual function in patients with Parkinson's disease. Journal of Neurology, Neurosurgery & Psychiatry. 1991;54(10):942.
Sipski M, Alexander C, Guo X, et al. Cardiovascular effects of sildenafil in men with SCIs at and above T6. Topics in Spinal Cord Injury Rehabilitation. 2003;8(3):26-34.
Siraj QH, Bomanji J, Akhtar MA, et al. Quantitation of pharmacologically-induced penile erections: The value of radionuclide phallography in the objective evaluation of erectile haemodynamics. Nucl Med Commun. 1990;11(6):445-458. [pmid: 2385430].
Slob AK, Dohle GR, Incrocci L. ‘Sildenafil and pharmaco-penile duplex ultrasonography’ by Speel et al: Inconclusive results. Int J Impot Res. 2002;14(2):136-137. [pmid: 11979331].
Slob A, Koos Steyvers, Christel L, et al. Routine psychophysiological screening of 384 men with erectile dysfunction. J Sex Marital Ther. 1998;24(4):273-279. [pmid: 9805287].
Smith KJ, Roberts MS. The cost-effectiveness of sildenafil. Ann Intern Med. 2000;132(12):933-937. [pmid: 10858175].
Smith KM, Romanelli F. Recreational use and misuse of phosphodiesterase 5 inhibitors. [Review] [56 refs]. Journal of the American Pharmacists Association: JAPhA. 2005;45(1):63-72. [pmid: 15730119].
Sobh MA, Abd el, Hamid I, et al. Effect of erythropoietin on sexual potency in chronic haemodialysis patients. A preliminary study. Scand J Urol Nephrol. 1992;26(2):181-185. [pmid: 1626208].
Sogari PR, Teloken C, Souto CA. Atropine role in the pharmacological erection test: study of 228 patients. Br J Urol. 1997;158(5):1760-1763.
Sohle GR. Re: The age-related decrease in testosterone is significantly exacerbated in obese men with the metabolic syndrome. What are the implications for the relatively high incidence of erectile dysfunction observed in these men?. Eur Urol. 2007;51(5):1440. [pmid: 17494117].
Sohn Michael, Sikora Richard. Ginkgo biloba extract in the therapy of erectile dysfunction. Journal of Sex Education & Therapy. 1991;17(1):53-61.
Solursh L, Solursh DS. Male erectile disorders in Vietnam combat veterans with chronic post-traumatic stress disorder. International Journal of Adolescent Medicine & Health. 1994;7(2):119-124. [pmid: 22912152].
Solursh Lionel P, Solursh Diane S. Male erectile disorders in Vietnam combat veterans with chronic post-traumatic stress disorder. Int J Adolesc Med Health. 1994;7(2):119-124. [pmid: 22912152].
Sonda LP, Mazo R, Chancellor MB. The role of yohimbine for the treatment of erectile impotence. J Sex Marital Ther. 1990;16(1):15-21. [pmid: 2370671].
Sonksen J, Biering-Sorensen F. Transcutaneous nitroglycerin in the treatment of erectile dysfunction in spinal cord injured. Paraplegia. 1992;30(8):554-557. [pmid: 1522996].
Sorbera LA, Martin L, Rabasseda X, et al. Vardenafil. Treatment of erectile dysfunction. Phosphodiesterase 5 inhibitor. Drugs of the Future. 2001;26(2):141-144.
Sparwasser C, Drescher P, Pust RA, et al. Long-term results of therapy with intracavernousal injections and penile venous surgery in chronic erectile dysfunction. Scand J Urol Nephrol Suppl. 1994;157(Suppl):107-112. [pmid: 7939440].
Speakman MT, Kloner RA. Viagra and cardiovascular disease. Journal of Cardiovascular Pharmacology & Therapeutics. 1999;4(4):259-267. [pmid: 10684547].
Srilatha B, Adaikan PG, Chong YS. Relevance of oestradiol-testosterone balance in erectile dysfunction patients' prognosis. Singapore Med J. 2007;48(2):114-118. [pmid: 17304389].
Stas SN, Anastasiadis AG, Fisch H, et al. Urologic aspects of andropause. Urology. 2003;61(2):261-266. [pmid: 12597927].
Steers WD. Tachyphylaxis and phosphodiesterase type 5 inhibitors.[comment]. Br J Urol. 2002;168(1):207.
Steers WD. Viagra - After one year. Urology. 1999;54(1):12-17. [pmid: 10414719].
Steidle C, Witt MA, Matrisciano J, et al. Sexual functioning and satisfaction in nonresponders to testosterone gel: Potential effectiveness of retreatment in hypogonadal males. Clin Cornerstone. 2005;7(Suppl 4):S20-S25. [pmid: 16651204].
Steiger A, Holsboer F, Benkert O. Studies of nocturnal penile tumescence and sleep electroencephalogram in patients with major depression and in normal controls. Acta Psychiatr Scand. 1993;87(5):358-363. [pmid: 8517177].
Steiger Axel, Benkert O, Holsboer F. Effects of long-term treatment with the MAO-A inhibitor moclobemide on sleep EEG and nocturnal hormonal secretion in normal men. Neuropsychobiology. 1994;30(23):101-105. [pmid: 7800155].
Stief CG, Uckert S, Jonas U. Strategies in the oral pharmacotherapy of male erectile dysfunction viewed from bench and bedside (Part II). The Journal of Mens Health & Gender. 2005;2(3):325-332.
Stief CG, Uckert S, Becker AJ, et al. The effect of the specific phosphodiesterase (PDE) inhibitors on human and rabbit cavernous tissue in vitro and in vivo. Br J Urol. 1998;159(4):1390-1393.
Stief C, Padley RJ, Perdok RJ, et al. Cross-study review of the clinical efficacy of apomorphine SL 2 and 3 mg: Pooled data from three placebo-controlled, fixed-dose crossover studies. European Urology Supplements. 2002;1(3):12-20.
Stolk EA, Busschbach JJ, Caffa M, et al. Cost utility analysis of sildenafil compared with papaverine-phentolamine injections.[see comment]. BMJ. 2000;320(7243):1165-1168. [pmid: 10784537].
Strachan MW, Teoh WL, Don-Wauchope AC, et al. Clinical and radiological features of patients with macroprolactinaemia. Clin Endocrinol (Oxf). 2003;59(3):339-346. [pmid: 12919157].
Strahilevitz J, Rahav G, Schroers HJ, et al. An outbreak of Phialemonium infective endocarditis linked to intracavernous penile injections for the treatment of impotence. Clin Infect Dis. 2005;40(6):781-786. [pmid: 15736008].
Stroberg P, Murphy A, Costigan T. Switching patients with erectile dysfunction from sildenafil citrate to tadalafil: results of a European multicenter, open-label study of patient preference. Clin Ther. 2003;25(11):2724-2737. [pmid: 14693300].
Struthers AD. Aldosterone blockade in heart failure. J Renin Angiotensin Aldosterone Syst. 2004;5(SUPPL. 1):S23-S27. [pmid: 15526239].
Stuckey BGA. Tadalafil phase 3 experience. European Urology Supplements. 2002;1(8):25-30.
Suetomi T, Endo F, Takeshima H, et al. Evaluation of the effectiveness of sildenafil using questionnaire methods versus audio-visual sexual stimulation. Int J Urol. 2005;12(4):369-373. [pmid: 15948724].
Suzuki F, Shimizu C, Umetsu M, et al. Adult-onset idiopathic hypogonadotropic hypogonadism due to isolated pituitary gonadotropin deficiency. Adv Intern Med. 2004;43(7):571-574.
Svartberg J, Aasebo U, Hjalmarsen A, et al. Testosterone treatment improves body composition and sexual function in men with COPD, in a 6-month randomized controlled trial. Respir Med. 2004;98(9):906-913. [pmid: 15338805].
Swartz DA, Todd MW. Intracavernous papaverine and glaucoma.[see comment]. JAMA. 1990;264(5):570. [pmid: 2366292].
Szucs A, Janszky J, Barsi P, et al. Sleep-related painful erection is associated with neurovascular compression of basal forebrain [5]. J Neurol. 2002;249(4):486-487. [pmid: 11967660].
T'Sjoen G, Feyen E, De Kuyper P, et al. Self-referred patients in an aging male clinic: much more than androgen deficiency alone. Aging Male. 2003;6(3):157-165. [pmid: 14628496].
Tam SW, Worcel M, Wyllie M. Yohimbine: a clinical review. [Review] [152 refs]. Pharmacol Ther. 2001;91(3):215-243. [pmid: 11744068].
Tarhan F, Canguven O, Kuyumcuoglu U. Intracavernous sodium nitroprusside (SNP) versus papaverine/phentolamine in erectile dysfunction: a comparative study of short-term efficacy and side-effects.[comment]. Br J Sex Med. 2006;3(2):377.
Tarhan F, Kuyumcuoglu U, Kolsuz A, et al. Effect of intracavernosal sodium nitroprusside in impotence. Urol Int. 1996;56(4):211-214. [pmid: 8776816].
Tas A, Dilek K, Gullulu M et al. Treatment of erectile dysfunction in hemodialysis patients and effects of sildenafil [abstract]. XXXVIII Congress of the European Renal Association European Dialysis & Transplant Association June 24–27 2003;2001, Vienna, Austria 131p. 2003.
Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005;88(3):241-254. [pmid: 16162361].
Teillac P, Bono AV, Irani J, et al. The role of luteinizing hormone-releasing hormone therapy in locally advanced prostate cancer and biochemical failure: Considerations for optimal use. Clin Ther. 2005;27(3):273-285. [pmid: 15878381].
Teloken PE, Smith EB, Lodowsky C, et al. Defining association between sleep apnea syndrome and erectile dysfunction. Urology. 2006;67(5):1033-1037. [pmid: 16698364].
Thadani U, Smith W, Nash S, et al. The effect of vardenafil, a potent and highly selective phosphodiesterase-5 inhibitor for the treatment of erectile dysfunction, on the cardiovascular response to exercise in patients with coronary artery disease. J Am Coll Cardiol. 2002;40(11):2006-2012. [pmid: 12475462].
Thaveundayil JX, Hambalek R, Ng Ying, et al. Prolonged penile erections induced by hydroxyzine: Possible mechanism of action. Neuropsychobiology. 1994;30(1):4-6. [pmid: 7969858].
Thrasher JB. What's new in urology. J Am Coll Surg. 2005;201(3):438-448. [pmid: 16125079].
Tindall B, Forde S, Goldstein D, et al. Sexual dysfunction in advanced HIV disease. AIDS Care. 1994;6(1):105-107. [pmid: 8186272].
Tomlinson J. Viagra and its use in cardiovascular disease.[erratum appears in J Hum Hypertens 2000 Apr;14(4):283]. [Review] [11 refs]. J Hum Hypertens. 1999;13(9):593-594. [pmid: 10482968].
Tomova A, Kumanov P. Are dehydroepiandrosterone sulphate and lipids associated with erectile dysfunction? [References]. Maturitas. 2005;50(4):294-299. [pmid: 15780529].
Tordjman G. NO/Pg E1: a new association in the treatment of erectile impotence. Contracept Fertil Sex (Paris) 1993;.21, pp.509–510, 1993.
Tosti A, Pazzaglia M, Soli M, et al. Evaluation of sexual function with an international index of erectile function in subjects taking finasteride for androgenetic alopecia.[see comment]. Arch Dermatol. 2004;140(7):857-858. [pmid: 15262698].
Traish AM, Goldstein I, Kim NN. Testosterone and erectile function: from basic research to a new clinical paradigm for managing men with androgen insufficiency and erectile dysfunction. Eur Urol. 2007;52(1):54-70. [pmid: 17329016].
Trinchieri A, Nicola M, Masini F, et al. Prospective comprehensive assessment of sexual function after retropubic non nerve sparing radical prostatectomy for localized prostate cancer. Arch Ital Urol Androl. 2005;77(4):219-223. [pmid: 16444937].
Truss MC, Becker AJ, Djamilian MH, et al. Role of the nitric oxide donor linsidomine chlorhydrate (SIN-1) in the diagnosis and treatment of erectile dysfunction. Urology. 1994;44(4):553-556. [pmid: 7941195].
Tsai SK, Hong CY. Intracavernosal metaraminol for treatment of intraoperative penile erection. Postgrad Med J. 1990;66(780):831-833. [pmid: 2099422].
Tsujimura A, Matsumiya K, Matsuoka Y, et al. Bioavailable testosterone with age and erectile dysfunction. Br J Urol. 2003;170(6 Pt 1):2345-2347.
Tuzgen S, Karamehmetoglu SS, Karacan I, et al. Use of sildenafil in the treatment of erectile dysfunction in patients with spinal cord injury. Neurosurgery Quarterly. 2006;16(1):40-43.
Tzivoni D, Klein J, Hisdai D, et al. The Israel Heart Society expert consensus document: The cardiac patient and sexual activity in the era of sildenafil (Viagra). Israel Medical Association Journal: Imaj. 2000;2(1):63-65. [pmid: 10892379].
Unnikrishnan AG, Rajaratnam S, Seshadri MS, et al. The ‘hook effect’ on serum prolactin estimation in a patient with macroprolactinoma. Neurol India. 2001;49(1):78-80. [pmid: 11303248].
Urciuoli R, Cantisani T A, CarliniI M et al. Prostaglandin E1 for treatment of erectile dysfunction. Cochrane Database Syst Rev 2004;(2):CD001784
Uygur MC, Arik AI, Altug U, et al. Effects of the 5 alpha-reductase inhibitor finasteride on serum levels of gonadal, adrenal, and hypophyseal hormones and its clinical significance: a prospective clinical study. Steroids. 1998;63(4):208-213. [pmid: 9589555].
Valdevenito R, Melman A. Intracavernous self-injection pharmacotherapy program: analysis of results and complications. Int J Impot Res. 1994;6(2):81-91. [pmid: 7951702].
van Basten JP, Van Driel MF, Hoekstra HJ, et al. Erectile dysfunction with chemotherapy.[comment]. Lancet. 2000;356(9224):169. [pmid: 10963279].
van Basten JP, Van Driel MF, Hoekstra HJ, et al. Erectile dysfunction with chemotherapy. Lancet. 2000;356(9224):169. [pmid: 10963279].
van Basten JP, Van Driel MF, Jonker-Pool G, et al. Sexual functioning in testosterone-supplemented patients treated for bilateral testicular cancer. Br J Urol. 1997;79(3):461-467. [pmid: 9117232].
Van Ahlen H, Peskar BA, Sticht G, et al. Pharmacokinetics of vasoactive substances administered into the human corpus cavernosum. Br J Urol. 1994;151(5):1227-1230.
Van Dijk M, Skrekas T, De La, et al. The association between lower urinary tract symptoms and sexual dysfunction: Fact or fiction?. Curr Opin Urol. 2005;15(1):39-44. [pmid: 15586029].
Van Moorselaar J. LUTS and Sexual Dysfunction: Implications for Management of BPH. European Urology Supplements. 2003;2(10):13-20.
Vardi M, Nini A. Phosphodiesterase inhibitors for erectile dysfunction in patients with diabetes mellitus. [Review][49 refs]. Cochrane Database Syst Rev 2007;(1):CD002187
Vatansever HS, Kayikcioglu O, Gumus B. Histopathologic effect of chronic use of sildenafil citrate on the choroid & retina in male rats. Indian J Med Res. 2003;117(MAY):211-215. [pmid: 14609049].
Verit A, Oguz H. Ophthalmic aspects of erectile dysfunction drugs [3]. Am J Ophthalmol. 2006;141(3):598. [pmid: 16490529].
Vick RN, Benevides M, Patel M, et al. The efficacy, safety and tolerability of intracavernous PNU-83757 for the treatment of erectile dysfunction. Br J Urol. 2002;167(6):2618-2623.
Vickers MA, De Nobrega AM, Dluhy RG. Diagnosis and treatment of psychogenic erectile dysfunction in a urological setting: Outcomes of 18 consecutive patients. Br J Urol. 1993;149(5 SUPPL.):1258-1261.
Vickers MA, Wright EA. Erectile dysfunction in the patient with diabetes mellitus. Am J Manag Care. 2004;10(1 SUPPL.):S3-S11. [pmid: 14974584].
Vidal J, Curcoll L, Roig T, et al. Intracavernous pharmacotherapy for management of erectile dysfunction in multiple sclerosis patients. Rev Neurol. 1995;23(120):269-271. [pmid: 7497173].
Vinik AI, Maser RE, Mitchell BD, et al. Diabetic autonomic neuropathy. [Review] [192 refs]. Diabetes Care. 2003;26(5):1553-1579. [pmid: 12716821].
Virag R. Intracavernous injection of papaverine for erectile failure. 1982. Br J Urol. 2002;167(2 Pt 2):1196.
Virag R, Floresco J, Richard C. Impairment of shear-stress-mediated vasodilation of cavernous arteries in erectile dysfunction. Int J Impot Res. 2004;16(1):39-42. [pmid: 14963469].
Vitezic D. A risk-benefit assessment of sildenafil in the treatment of erectile dysfunction. [Review] [72 refs]. Drug Saf. 2001;24(4):255-265. [pmid: 11330655].
Vlachopoulos C, Hirata K, O'Rourke MF. Effect of sildenafil on arterial stiffness and wave reflection. Vasc Med. 2003;8(4):243-248. [pmid: 15125484].
Vogt HJ, Brandl P, Kockott G, et al. Double-blind, placebo-controlled safety and efficacy trial with yohimbine hydrochloride in the treatment of nonorganic erectile dysfunction. Int J Impot Res. 1997;9(3):155-161. [pmid: 9315493].
Wagner G, Mulhall J. Pathophysiology and diagnosis of male erectile dysfunction. BJU International - Supplement. 2001;88(3):3-10.
Wagner G, Rabkin J, Rabkin R. Effects of testosterone replacement therapy on sexual interest, function, and behavior in HIV+ men. J Sex Res. 1997;34(1):27-33.
Wagner Gorm, Kaplan Helen, Singer. The new injection treatment for impotence: Medical and psychological aspects. Refuat Hapeh Vehashinayim 1993;x, 210 pp. Philadelphia, PA, US210
Wagrell L, Schelin S, Nordling J, et al. Three-year follow-up of feedback microwave thermotherapy versus TURP for clinical BPH: a prospective randomized multicenter study. Urology. 2004;64(4):698-702. [pmid: 15491704].
Wald M, Seftel AD, Ross LS, et al. Computational models for detection of erectile dysfunction. Br J Urol. 2005;173(1):167-170.
Waldbaum RS. The safety of PDE5 inhibitors in ED treatment: Putting cardiovascular concerns to rest. Cardiology Review. 2005;22(9):23-24.
Wang ZL, Shao SX, Li B, et al. Sildenafil versus prostaglandin E1 in the management of erectile dysfunction. Journal of Clinical Urology. 2002;17(7):347-349.
Wang Z, Liu BC, Chen B, et al. Randomized controlled study on erectile dysfunction treated by trazodone. Chinese Journal of Andrology. 2002;16(3):236-238.
Ware J, Catesby Rose F, Vincent McBrayer, et al. The acute effects of nefazodone, trazodone and buspirone on sleep and sleep-related penile tumescence in normal subjects. Sleep: Journal of Sleep Research & Sleep Medicine. 1994;17(6):544-550.
Watanabe T, Chancellor MB, Rivas DA, et al. Epidemiology of current treatment for sexual dysfunction in spinal cord injured men in the USA model spinal cord injury centers. J Spinal Cord Med. 1996;19(3):186-189. [pmid: 8819027].
Webb DJ, Freestone S, Allen MJ, et al. Sildenafil citrate and blood-pressure-lowering drugs: results of drug interaction studies with an organic nitrate and a calcium antagonist. Am J Cardiol. 1999;83(5A):21C-28C. [pmid: 10073779].
Webb DJ, Muirhead GJ, Wulff M, et al. Sildenafil citrate potentiates the hypotensive effects of nitric oxide donor drugs in male patients with stable angina. J Am Coll Cardiol. 2000;36(1):25-31. [pmid: 10898408].
Wegner HEH, Knispel HH, Meier T, et al. Nitric oxide donor, linsidomine chlorhydrate (SIN-1), in the diagnosis and treatment of erectile dysfunction: Critical appraisal and review of the literature. International Urology & Nephrology. 1995;27(5):621-628. [pmid: 8775048].
Weinhardt LS, Carey MP. Prevalence of erectile disorder among men with diabetes mellitus: Comprehensive review, methodological critique, and suggestions for future research. J Sex Res. 1996;33(3):205-214.
Weinsaft JW, Hickey K, Bokhari S, et al. Effects of tadalafil on myocardial blood flow in patients with coronary artery disease. Coron Artery Dis. 2006;17(6):493-499. [pmid: 16905960].
Weiske WH. Invasive diagnosis and therapy - Are they still reasonable in the age of sildenafil?. Andrologia. 1999;31(SUPPL. 1):95-97. [pmid: 10643526].
Wespes E, Rammal A, Garbar C. Sildenafil non-responders: haemodynamic and morphometric studies. Eur Urol. 2005;48(1):136-139. [pmid: 15967263].
Wessells H, Fuciarelli K, Hansen J, et al. Synthetic melanotropic peptide initiates erections in men with psychogenic erectile dysfunction: double-blind, placebo controlled crossover study. Br J Urol. 1998;160(2):389-393.
Wessells H, Gralnek D, Dorr R, et al. Effect of an alpha-melanocyte stimulating hormone analog on penile erection and sexual desire in men with organic erectile dysfunction. Urology. 2000;56(4):641-646. [pmid: 11018622].
Wheatley D. Triple-blind, placebo-controlled trial of Ginkgo biloba in sexual dysfunction due to antidepressant drugs. Hum Psychopharmacol. 2004;19(8):545-548. [pmid: 15378664].
Wilke DR, Parker C, Andonowski A, et al. Testosterone and erectile function recovery after radiotherapy and long-term androgen deprivation with luteinizing hormone-releasing hormone agonists. BJU Int. 2006;97(5):963-968. [pmid: 16542340].
Williams G. Male erectile dysfunction. Prescribers' Journal. 2000;40(1):49-58.
Williams T, Honeywell M, Branch E et al. Tadalafil in the treatment of erectile dysfunction. P & T 2004;29(5):
Wilt TJ, Fink HA. Is antidepressant plus sildenafil a recipe for priapism?. Postgrad Med. 2004;116(6):11-12. [pmid: 15620123].
Witt Deborah K. Yohimbine for erectile dysfunction. J Fam Pract. 1998;46(4):282-283. [pmid: 9564368].
Wood P L. Slow, tedious but essential: The need for incremental R&D. Current Drug Discovery 2004;(pp 31–35):-35.
Wyllie MG. The hunt for pink Viagra. BJU Int. 2005;95(1):181-182. [pmid: 15638919].
Wyllie MG. Let's hope for more in 2004. BJU Int. 2004;93(1):175-176. [pmid: 14678392].
Wyllie MG. The Second International Consultation on Erectile Dysfunction: Highlights from the pharmaceutical industry. BJU Int. 2003;92(6):645-646. [pmid: 14511053].
Wyllie MG. The genesis of a phytopharmaceutical industry (Mark II). BJU Int. 2003;91(7):721-722. [pmid: 12699492].
Yajima T, Yajima Y, Koppiker N, et al. No clinically important effects on intraocular pressure after short-term administration of sildenafil citrate (Viagra). Am J Ophthalmol. 2000;129(5):675-676. [pmid: 10844068].
Yaman O, Akand M, Gursoy A, et al. The effect of diabetes mellitus treatment and good glycemic control on the erectile function in men with diabetes mellitus-induced erectile dysfunction: a pilot study. Br J Sex Med. 2006;3(2):344-348.
Yaman O, Tokatli Z, Akand M, et al. Characteristics of sildenafil erections in healthy young men. Asian J Androl. 2005;7(4):395-398. [pmid: 16281087].
Yamanaka M, Shirai M, Shiina H, et al. Vascular endothelial growth factor restores erectile function through inhibition of apoptosis in diabetic rat penile crura. Br J Urol. 2005;173(1):318-323.
Yan JY, Yang WZ. A comparative effects of Sildenafil and Yohimbine for the treatment of erectile dysfunction. Chinese Journal of Andrology. 2000;14(2):103-105.
Yarkony GM. Enhancement of sexual function and fertility in spinal cord-injured males. [Review] [40 refs]. Am J Phys Med Rehabil. 1990;69(2):81-87. [pmid: 2184843].
Yassin AA, Saad F. Treatment of sexual dysfunction of hypogonadal patients with long-acting testosterone undecanoate (Nebido). [Review] [25 refs]. World J Urol. 2006;24(6):639-644. [pmid: 17048032].
Yassin AA, Saad F. Dramatic improvement of penile venous leakage upon testosterone administration. A case report and review of literature. Andrologia. 2006;38(1):34-37. [pmid: 16420241].
Yasumoto R, Nishisaka N, Sakakura T, et al. Ethanol embolization for impotent patients with venous leakage: A new technique and initial results. Minimally Invasive Therapy & Allied Technologies: Mitat. 1996;5(6):564-566.
Yeager J, Beihn RM. Retention and migration of alprostadil cream applied topically to the glans meatus for erectile dysfunction. Int J Impot Res. 2005;17(1):91-95. [pmid: 15538395].
Youssef AF, Fort FL, Ronsen B, et al. Evaluation of apomorphine HCl effects on reproductive endpoints: Studies in male rats and dogs. J Toxicol Sci. 1999;51(2):273-279.
Zaslau S, Nicolis C, Galea G, et al. A simplified pharmacologic erection program for patients with spinal cord injury. J Spinal Cord Med. 1999;22(4):303-307. [pmid: 10751135].
Zasler ND. Therapeutic approaches to sexual impotence. Hospital Practice (Office Edition). 1988;23(7):197-200.
Zhao L. Clinical observation on the therapeutic effects of heavy moxibustion plus point-injection in treatment of impotence. J Tradit Chin Med. 2004;24(2):126-127. [pmid: 15270266].
Zhigang Long, Xiaowei Liu, Shengbo Lu. Therapy of impotence with traditional Chinese medicine. Journal of Sex Education & Therapy. 1994;20(2):140-143.
Ziegler D. Management of erectile dysfunction in diabetic patients. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):58-65.
Zini Dante, Carani Cesare, Baldini Augusto, et al. Sexual behavior of men with isolated hypogonadotropic hypogonadism or prepubertal anterior panhypopituitarism. Horm Behav. 1990;24(2):174-185. [pmid: 2365300].
Zlotta AR, Teillac P, Raynaud JP, et al. Evaluation of male sexual function in patients with Lower Urinary Tract Symptoms (LUTS) associated with Benign Prostatic Hyperplasia (BPH) treated with a phytotherapeutic agent (Permixon), Tamsulosin or Finasteride. Eur Urol. 2005;48(2):269-276. [pmid: 15939527].
Zusman RM. Cardiovascular data on sildenafil citrate: introduction.[erratum appears in Am J Cardiol 1999 Jul 15;84(2):244]. Am J Cardiol. 1999;83(5A):1C-2C. [pmid: 10073775].
Zusman RM, Morales A, Glasser DB, et al. Overall cardiovascular profile of sildenafil citrate. [Review] [33 refs]. Am J Cardiol. 1999;83(5A):35C-44C.
Zusman RM, Prisant LM, Brown MJ. Effect of sildenafil citrate on blood pressure and heart rate in men with erectile dysfunction taking concomitant antihypertensive medication. Sildenafil Study Group. J Hypertens. 2000;18(12):1865-1869. [pmid: 11132612].

## Observational injection study with < 6 months followup in duration

Bancroft J, Smith G, Munoz M, et al. Erectile response to visual erotic stimuli before and after intracavernosal papaverine, and its relationship to nocturnal penile tumescence and psychometric assessment. Br J Urol. 1991;68(6):629-638. [pmid: 1773296].
Beretta G, Marzotto M, Zanollo A, et al. Office treatment: intracavernous injections of prostaglandin E1 (PG E1) and improvement of spontaneous erections. Acta Eur Fertil. 1991;22(4):221-223. [pmid: 1844326].
Bird TD, Lipe HP, Crabtree LD. Impotence associated with the Charcot-Marie-Tooth syndrome. Eur Neurol. 1994;34(3):155-157. [pmid: 8033941].
Brown SL, Haas CA, Koehler M, et al. Hepatotoxicity related to intracavernous pharmacotherapy with papaverine. Urology. 1998;52(5):844-847. [pmid: 9801111].
Casella R, Deckart A, Bachmann A, et al. The patient's self-evaluation better predicts the degree of erectile dysfunction than the response to intracavernous alprostadil testing. Urol Int. 2004;72(3):216-220. [pmid: 15084765].
Chatterjee R, Kottaridis PD, McGarrigle HH, et al. Management of erectile dysfunction by combination therapy with testosterone and sildenafil in recipients of high-dose therapy for haematological malignancies. Bone Marrow Transplant. 2002;29(7):607-610. [pmid: 11979311].
Chun SS, Fenemore J, Heaton JP, et al. Enhancement of erectile responses to vasoactive drugs by a variable amplitude oscillation device. Int J Impot Res. 1996;8(4):221-225. [pmid: 8981171].
Dinsmore WW, Alderdice DK. Vasoactive intestinal polypeptide and phentolamine mesylate administered by autoinjector in the treatment of patients with erectile dysfunction resistant to other intracavernosal agents. Br J Urol. 1998;81(3):437-440. [pmid: 9523666].
Fein RL. Classification of sexual dysfunction for management of intracavernous medication-induced erections.[see comment]. Br J Urol. 1990;143(2):298-301.
Goonawardena SA, de Silva WA, Ketheeswaran T. Pharmacologically induced penile erections in the assessment and treatment of erectile impotence: a preliminary study of 100 patients. Ceylon Med J. 1997;42(2):72-74. [pmid: 9257465].
Greco E, Balbi PP, Virag R. Self intra-cavernous injections as a successful treatment in pure neurogenic impotence. Riv Neurol. 1991;61(1):35-38. [pmid: 1857921].
Kadioglu A, Erdogru T, Tellaloglu S. Combined intracavernous injection of papaverine and stimulation (CIS) test. J Androl. 1994;15(Suppl):50S-53S. [pmid: 7721678].
Katlowitz NM, Albano GJ, Morales P, et al. Potentiation of drug-induced erection with audiovisual sexual stimulation. Urology. 1993;41(5):431-434. [pmid: 8488610].
Katlowitz N, Albano GJ, Patsias G, et al. Effect of multidose intracorporeal injection and audiovisual sexual stimulation in vasculogenic impotence. Urology. 1993;42(6):695-697. [pmid: 8256402].
Kim JM, Joh YD, Huh JD, et al. Doppler sonography of the penile cavernosal artery: comparison of intraurethral instillation and intracorporeal injection of prostaglandin E1. J Clin Ultrasound. 2001;29(5):273-278. [pmid: 11486321].
Knispel HH. Penile venous surgery in impotence: results in highly selected cases. Urol Int. 1991;47(3):144-148. [pmid: 1771702].
Kromann-Andersen B. Intracavernosal pharmacotherapy with injection pen. Lancet. 1988;1(85756):54-59. [pmid: 2891913].
Mansi MK, Alkhudair WK, Huraib S. Treatment of erectile dysfunction after kidney transplantation with intracavernosal self-injection of prostaglandin E1. Br J Urol. 1998;159(6):1927-1930.
McMahon CG. A pilot study of the role of intracavernous injection of vasoactive intestinal peptide (VIP) and phentolamine mesylate in the treatment of erectile dysfunction. Int J Impot Res. 1996;8(4):233-236. [pmid: 8981173].
McMahon CG. Priapism associated with concurrent use of phosphodiesterase inhibitor drugs and intracavernous injection therapy. Int J Impot Res. 2003;15(5):383-384. [pmid: 14562142].
Metawea B, El-Nashar AR, Gad-Allah A, et al. Intracavernous papaverine/phentolamine-induced priapism can be accurately predicted with color Doppler ultrasonography. Urology. 2005;66(4):858-860. [pmid: 16230153].
Mirone V, Imbimbo C, Fabrizio F, et al. Ketanserin plus prostaglandin E1 (PGE-1) as intracavernosal therapy for patients with erectile dysfunction unresponsive to PGE-1 alone. Br J Urol. 1996;77(5):736-739. [pmid: 8689122].
Nagai A, Kusumi N, Tsuboi H, et al. Intracavernous injection of prostaglandin E1 is effective in patients with erectile dysfunction not responding to phosphodiseterase 5 inhibitors. Acta Med Okayama. 2005;59(6):279-280. [pmid: 16418771].
Nalesnik JG, Jones L, Kraus SR. Group B streptococcal septicemia following intracavernous injection therapy for erectile dysfunction in diabetes. Br J Urol. 2004;172(1):151-152.
Pagani E, Puech-Leao P, Glina S, et al. The value of a second injection on the pharmaco-induced erection test. Int J Impot Res. 1997;9(3):167-168. [pmid: 9315495].
Price DE, Cooksey G, Jehu D, et al. The management of impotence in diabetic men by vacuum tumescence therapy. Diabet Med. 1991;8(10):964-967. [pmid: 1838050].
Rodilla F, Fuentes MD, Chuan P, et al. Penile self-injection for impotence in patients after radical cystectomy. Journal of Clinical Pharmacy & Therapeutics. 1994;19(6):359-360. [pmid: 7876367].
Rodrigues M, Granegger S, O'Grady J, et al. Accumulation of platelets as a key mechanism of human erection. A scintigraphic study in patients with erectile dysfunction receiving intracavernous injection of PGE1, papaverine/phentolamine. Advances in Experimental Medicine & Biology. 1997;43:379-82.
Schouman M, Lacroix P, Amer M. Suppression of prostaglandin E1-induced pain by dilution of the drug with lidocaine before intracavernous injection. Br J Urol. 1992;148(4):1266.
Sparwasser C, Treiber U, Bahren W, et al. Postoperative erectile dysfunction; evaluation and treatment with intracavernous vasoactive injections. Progress in Clinical & Biological Research. 1991;370:349-354. [pmid: 1924468].
Stief CG, Holmquist F, Djamilian M, et al. Preliminary results with the nitric oxide donor linsidomine chlorhydrate in the treatment of human erectile dysfunction. Br J Urol. 1992;148(5):1437-1440.
Stief CG, Wetterauer U, Schaebsdau FH, et al. Calcitonin-gene-related peptide: a possible role in human penile erection and its therapeutic application in impotent patients. Br J Urol. 1991;146(4):1010-1014.
Vickers MA, De Nobrega AM, Dluhy RG. Diagnosis and treatment of psychogenic erectile dysfunction in a urological setting: Outcomes of 18 consecutive patients. Br J Urol. 1993;149(5 SUPPL.):1258-1261.
Weiss JN, Ravalli R, Badlani GH. Intracavernous pharmacotherapy in psychogenic impotence. Urology. 1991;37(5):441-443. [pmid: 1708925].

## Observational injection study > or = to 6 months in duration

al-Juburi AZ, O'Donnell PD. Follow up outcome of intracavernous papaverine. J Ark Med Soc. 1990;86(10):383-385. [pmid: 2138146].
Armstrong DK, Convery AG, Dinsmore WW. Reasons for patient drop-out from an intracavernous auto-injection programme for erectile dysfunction. Br J Urol. 1994;74(1):99-101. [pmid: 8044533].
Chang DW, Wood CG, Kroll SS, et al. Cavernous nerve reconstruction to preserve erectile function following non-nerve-sparing radical retropubic prostatectomy: a prospective study. Keisei Geka. 2003;111(3):1174-1181.
Chen J, Godschalk MF, Katz PG, et al. Incidence of penile pain after injection of a new formulation of prostaglandin E1.[see comment]. Br J Urol. 1995;154(1):77-79.
Chen J, Godschalk MF, Katz PG, et al. Combining intracavernous injection and external vacuum as treatment for erectile dysfunction.[see comment]. Br J Urol. 1995;153(5):1476-1477.
Cooper AJ. Evaluation of I-C papaverine in patients with psychogenic and organic impotence. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 1991;36(8):574-578. [pmid: 1742710].
Dhabuwala CB, Kerkar P, Bhutwala A, et al. Intracavernous papaverine in the management of psychogenic impotence. Arch Androl. 1990;24(2):185-191. [pmid: 2327828].
Fedele D, Coscelli C, Cucinotta D, et al. Management of erectile dysfunction in diabetic subjects: results from a survey of 400 diabetes centres in Italy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14(5):277-282.
Fein RL. Classification of sexual dysfunction for management of intracavernous medication-induced erections.[see comment]. Br J Urol. 1990;143(2):298-301.
Fugl-Meyer AR, Lodnert G, Branholm IB, et al. On life satisfaction in male erectile dysfunction. Int J Impot Res. 1997;9(3):141-148. [pmid: 9315491].
Godschalk M, Gheorghiu D, Chen J, et al. Long-term efficacy of a new formulation of prostaglandin E1 as treatment for erectile failure. Br J Urol. 1996;155(3):915-917.
Govier FE, McClure RD, Weissman RM, et al. Experience with triple-drug therapy in a pharmacological erection program.[see comment]. Br J Urol. 1993;150(6):1822-1824.
Incrocci L, Hop WC, Slob AK. Visual erotic and vibrotactile stimulation and intracavernous injection in screening men with erectile dysfunction: a 3 year experience with 406 cases. Int J Impot Res. 1996;8(4):227-232. [pmid: 8981172].
Irwin MB, Kata EJ. High attrition rate with intracavernous injection of prostaglandin E1 for impotency. Urology. 1994;43(1):84-87. [pmid: 8284888].
Jiann BP, Yu CC, Su CC. Impact of introduction of sildenafil on other treatment modalities for erectile dysfunction: A study of nationwide and local hospital sales. Int J Impot Res. 2004;16(6):527-530. [pmid: 15229626].
Kattan SA. The acceptance of satisfaction of Saudi males to vasoactive autoinjection intracavernous therapy, external negative pressure device and penile prosthesis in the treatment of erectile dysfunction. Ann Saudi Med. 2002;22(34):149-152. [pmid: 17159384].
Knispel HH, Huland H. Influence of cause on choice of therapy in 174 patients with erectile dysfunction. Br J Urol. 1992;147(5):1274-1276.
Lim PH, Ng FC. Erectile dysfunction in Singapore men: presentation, diagnosis, treatment and results. Ann Acad Med Singapore. 1992;21(2):248-253. [pmid: 1519896].
Lottman PE, Hendriks JC, Vruggink PA, et al. The impact of marital satisfaction and psychological counselling on the outcome of ICI-treatment in men with ED. Int J Impot Res. 1998;10(2):83-87. [pmid: 9647943].
Lundberg L, Olsson JO, Kihl B. Long-term experience of self-injection therapy with prostaglandin E1 for erectile dysfunction. Scand J Urol Nephrol. 1996;30(5):395-397. [pmid: 8936629].
Maniam P, Seftel AD, Corty EW, et al. Nocturnal penile tumescence activity unchanged after long-term intracavernous injection therapy. Br J Urol. 2001;165(3):830-832.
Mark SD, Keane TE, Vandemark RM, et al. Impotence following pelvic fracture urethral injury: incidence, aetiology and management. Br J Urol. 1995;75(1):62-64. [pmid: 7850299].
Montorsi F, Guazzoni G, Bergamaschi F, et al. Effectiveness and safety of multidrug intracavernous therapy for vasculogenic impotence. Urology. 1993;42(5):554-558. [pmid: 7694416].
Montorsi F, Guazzoni G, Bergamaschi F, et al. Four-drug intracavernous therapy for impotence due to corporeal veno-occlusive dysfunction. Br J Urol. 1993;149(5 Pt 2):1291-1295.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Intracavernous vasoactive pharmacotherapy: the impact of a new self-injection device.[see comment]. Br J Urol. 1993;150(6):1829-1832.
Mulhall JP, Jahoda AE, Cairney M, et al. The causes of patient dropout from penile self-injection therapy for impotence. Br J Urol. 1999;162(4):1291-1294.
Mulhall JP, Land S, Parker M, et al. The use of an erectogenic pharmacotheraphy regimen following radical prostatectomy improves recovery of spontaneous erectile function. Br J Sex Med. 2005;2(4):532-542.
Perimenis P, Athanasopoulos A, Geramoutsos I, et al. The incidence of pharmacologically induced priapism in the diagnostic and therapeutic management of 685 men with erectile dysfunction. Urol Int. 2001;66(1):27-29. [pmid: 11150947].
Rowland DL, Boedhoe HSM, Dohle G, et al. Intracavernosal self-injection therapy in men with erectile dysfunction: Satisfaction and attrition in 119 patients. Int J Impot Res. 1999;11(3):145-151. [pmid: 10404283].
Sparwasser C, Treiber U, Bahren W, et al. Postoperative erectile dysfunction; evaluation and treatment with intracavernous vasoactive injections. Progress in Clinical & Biological Research. 1991;370:349-354. [pmid: 1924468].
Speckens AE, Kattemolle MR, Hengeveld MW, et al. A prospective long-term follow-up study of patients evaluated for erectile dysfunction: outcome and associated factors. Int J Impot Res. 1995;7(2):101-110. [pmid: 7496438].
Tariq SH, Haleem U, Omran ML, et al. Erectile dysfunction: Etiology and treatment in young and old patients. Clin Geriatr Med. 2003;19(3):539-551. [pmid: 14567006].
Turner LA, Althof SE. The clinical effectiveness of self-injection and external vacuum devices in the treatment of erectile dysfunction: a six-month comparison. Psychiatr Med. 1992;10(2):283-293. [pmid: 1377397].
Virag R. Intracavernous injection of papaverine for erectile failure. 1982. Br J Urol. 2002;167(2 Pt 2):1196.
Weidner W, Schroeder-Printzen I, Fischer C, et al. Experience in the treatment of erectile dysfunction using the intracavernosal self-injection of papaverine: Results of a prospective study after a median follow-up of 42 months involving 135 patients and 10766 injections. World J Urol. 1992;10(3):179-182.
Weiss JN, Badlani GH, Ravalli R, et al. Reasons for high drop-out rate with self-injection therapy for impotence. Int J Impot Res. 1994;6(3):171-174. [pmid: 7735362].

## Not relevant by study design

Allan CA, McLachlan RI. Age-related changes in testosterone and the role of replacement therapy in older men. Clin Endocrinol (Oxf). 2004;60(6):653-670. [pmid: 15163327].
Anderson DC, Seifert CF. Topical nitrate treatment of impotence. [Review] [17 refs]. Ann Pharmacother. 1993;27(10):1203-1205. [pmid: 8251690].
Anonymous. Sildenafil for erectile dysfunction. Drug Ther.Bull 1998;36(11):81–84.
Anonymous. Vardenafil (levitra) for erectile dysfunction. Medical Letter on Drugs & Therapeutics 2003;45(1166):77–78.
Anonymous. Vasoactive intestinal peptide/phentolamine. Invicorp, vasopotin. Drugs in R &D 1999;2(6):436–438.
Berner M M, Kriston L, Harms A. Efficacy of PDE-5-inhibitors for erectile dysfunction. A comparative meta-analysis of fixed-dose regimen randomized controlled trials administering the International Index of Erectile Function in broad-spectrum populations. Int J Impot Res 2005;
Blanker MH, Thomas S, Bohnen AM. Systematic review of Viagra RCTs. Br J Gen Pract. 2002;52(477):329. [pmid: 11942454].
Bolona ER, Uraga MV, Haddad RM, et al. Testosterone use in men with sexual dysfunction: a systematic review and meta-analysis of randomized placebo-controlled trials. Mayo Clin Proc. 2007;82(1):20-28. [pmid: 17285782].
Burls A, Gold L, Clark W. Systematic review of randomised controlled trials of sildenafil (Viagra) in the treatment of male erectile dysfunction. Br J Gen Pract. 2001;51(473):1004-1012. [pmid: 11766850].
Calof OM, Singh AB, Lee ML, et al. Adverse events associated with testosterone replacement in middle-aged and older men: A meta-analysis of randomized, placebo-controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60(11):1451-1457.
Carey MP, Johnson BT. Effectiveness of yohimbine in the treatment of erectile disorder: four meta-analytic integrations. Arch Sex Behav. 1996;25(4):341-360. [pmid: 8836468].
Carson CC, Burnett AL, Levine LA, et al. The efficacy of sildenafil citrate (Viagra) in clinical populations: an update. Urology. 2002;60(2 Suppl 2):12-27. [pmid: 12414330].
Chen CT, Valicenti RK, Lu J, et al. Does hormonal therapy influence sexual function in men receiving 3D conformal radiation therapy for prostate cancer?. Int J Radiat Oncol Biol Phys. 2001;50(3):591-595. [pmid: 11395224].
Chiang HS, Kao YH, Sheu MT. Papaverine and prostaglandin E1 gel applications for impotence. Ann Acad Med Singapore. 1995;24(5):767-769. [pmid: 8579329].
Crowe SM, Streetman DS. Vardenafil treatment for erectile dysfunction. [Review] [43 refs]. Ann Pharmacother. 2004;38(1):77-85. [pmid: 14742800].
Derry F, Hultling C, Seftel AD, et al. Efficacy and safety of sildenafil citrate (Viagra) in men with erectile dysfunction and spinal cord injury: a review. Urology. 2002;60(2 Suppl 2):49-57. [pmid: 12414333].
Ernst E, Pittler MH. Yohimbine for erectile dysfunction: a systematic review and meta-analysis of randomized clinical trials. J Urol. 1998;159(2):433-436. [pmid: 9649257].
Escobar-Jimenez F. [Efficacy and safety of sildenafil in men with type 2 diabetes mellitus and erectile dysfunction]. Med Clin (Barc). 2002;119(4):121-124. [pmid: 12106522].
Fink HA, Mac Donald R, Rutks IR, et al. Sildenafil for male erectile dysfunction: a systematic review and meta-analysis. Arch Intern Med. 2002;162(12):1349-1360. [pmid: 12076233].
Fink HA, MacDonald R, Rutks IR, et al. Trazodone for erectile dysfunction: a systematic review and meta-analysis. BJU Int. 2003;92(4):441-446. [pmid: 12930437].
Hellstrom WJ. Vardenafil: a new approach to the treatment of erectile dysfunction. [Review] [37 refs]. Curr Urol Rep. 2003;4(6):479-487. [pmid: 14622502].
Holmes S. Tadalafil: a new treatment for erectile dysfunction. BJU Int. 2003;91(6):466-468. [pmid: 12656894].
Isidori AM, Giannetta E, Gianfrilli D, et al. Effects of testosterone on sexual function in men: results of a meta-analysis. Clin Endocrinol (Oxf). 2005;63(4):381-394. [pmid: 16181230].
Jain P, Rademaker AW, McVary KT. Testosterone supplementation for erectile dysfunction: results of a meta-analysis. Br J Urol. 2000;164(2):371-375.
Keating GM, Scott LJ. Vardenafil: a review of its use in erectile dysfunction. Drugs. 2003;63(23):2673-2703. [pmid: 14636086].
Keating GM, Scott LJ. Spotlight on vardenafil in erectile dysfunction. Drugs Aging. 2004;21(2):135-140. [pmid: 14960129].
Kloner RA. Cardiovascular effects of the 3 phosphodiesterase-5 inhibitors approved for the treatment of erectile dysfunction. [Review] [57 refs]. Circulation. 2004;110(19):3149-3155. [pmid: 15533876].
Langtry HD, Markham A. Sildenafil: a review of its use in erectile dysfunction. Drugs. 1999;57(6):967-989. [pmid: 10400408].
Lewis RW. Intraurethral and topical agents. Med Actual. 2000;36(23):113-119.
Licht M R, Schover L R. Sildenafil (Viagra) for treating male erectile dysfunction. Cleve Clin J Med 1998;65(6):
Markou S, Perimenis P, Gyftopoulos K, et al. Vardenafil (Levitra) for erectile dysfunction: a systematic review and meta-analysis of clinical trial reports. Int J Impot Res. 2004;16(6):470-478. [pmid: 15229625].
McMahon CG. Topiglan: MacroChem. Curr Opin Investig Drugs. 2002;3(4):602-606.
Mikhail N. Does Testosterone Have a Role in Erectile Function?. Am J Med. 2006;119:373-382. [pmid: 16651047].
Montorsi F, McCullough A. Efficacy of sildenafil citrate in men with erectile dysfunction following radical prostatectomy: A systematic review of clinical data. Br J Sex Med. 2005;2(5):658-667.
Moore R A, Derry S, McQuay H J. Indirect comparison of interventions using published randomised trials: systematic review of PDE-5 inhibitors for erectile dysfunction. [Review][77 refs]. BMC Urol 2005;518
Moore R A, Edwards J E, McQuay H J. Sildenafil (Viagra) for male erectile dysfunction: a meta-analysis of clinical trial reports. BMC Urol. 2002;26
Morales A, Gingell C, Collins M, et al. Clinical safety of oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):69-73. [pmid: 9647940].
Padma-Nathan H, Eardley I, Kloner R A et al. A 4-year update on the safety of sildenafil citrate (Viagra). [Review][88 refs]. Urology 2002;60(2:Suppl 2):Suppl-90.
Rashid A. The efficacy and safety of PDE5 inhibitors. [Review] [30 refs]. Clin Cornerstone. 2005;7(1):47-56. [pmid: 16156423].
Rudkin L, Taylor M J, Hawton K. Strategies for managing sexual dysfunction induced by antidepressant medication. [Review][61 refs]. Cochrane Database Syst Rev 2004;(4):CD003382
Setter SM, Iltz JL, Fincham JE, et al. Phosphodiesterase 5 inhibitors for erectile dysfunction. [Review] [75 refs]. Ann Pharmacother. 2005;39(78):1286-1295. [pmid: 15941818].
Sommer F, Engelmann U. Vardenafil: Bayer Yakuhin. Curr Opin Investig Drugs. 2002;3(4):607-613.
Sternbach Harvey. Age-associated testosterone decline in men: Clinical issues for psychiatry. Am J Psychiatry. 1998;155(10):1310-1318. [pmid: 9766760].
Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005;88(3):241-254. [pmid: 16162361].
Tomsak R. PDE5 inhibitors and permanent visual loss. Int J Impot Res. 2005;17(6):547-549. [pmid: 16193072].
Tran D, Howes LG. Cardiovascular safety of sildenafil. Drug Saf. 2003;26(7):453-460. [pmid: 12735784].
Urciuoli R, Cantisani T A, CarliniI M et al. Prostaglandin E1 for treatment of erectile dysfunction. Cochrane Database Syst Rev 2004;(2):CD001784

## Not an original study, or population of interest, intervention of interest, or outcome of interest

Abdallah HM. Comparison of Alprostadil (Caverject) and a combination of vasoactive drugs as local injections for the treatment of erectile dysfunction. Int Urol Nephrol. 1998;30(5):617-620. [pmid: 9934808].
Abrams J. Time course of the interaction between tadalafil and nitrates.[comment]. J Am Coll Cardiol. 2004;43(11):2150-2151. [pmid: 15172433].
Adaikan PG, Chong YS, Chew SSL, et al. Male sexual dysfunction. Curr Obstet Gynaecol. 2000;10(1):23-28.
Adams MA, Perdok RJ, Padley RJ, et al. Safety and tolerability of apomorphine SL in men with cardiovascular disorders. European Urology Supplements. 2002;1(3):28-32.
Agelink MW, Schmitz T, Rembrink K, et al. Cardiovascular effects of sildenafil citrate (Viagra): a naturalistic cross-over study. Eur J Med Res. 2001;6(11):459-464. [pmid: 11726304].
Ahuja SK, Krane NK, Hellstrom WJ. Penile prostheses in the management of impotence in patients with end-stage renal disease. J La State Med Soc. 1998;150(1):32-34. [pmid: 9448384].
Aizenberg Dov, Gur Shay, Zemishlany Zvi, et al. Mianserin, a 5-HT-sub(2a/2c) and alpha -sub-2 antagonist, in the treatment of sexual dysfunction induced by serotonin reuptake inhibitors. Clin Neuropharmacol. 1997;20(3):210-214. [pmid: 9197943].
Aizenberg Dov, Weizman Abraham, Barak Yoram, et al. Sildenafil for selective serotonin reuptake inhibitor-induced erectile dysfunction in elderly male depressed patients. [References]. J Sex Marital Ther. 2003;29(4):297-303. [pmid: 14504018].
al-Juburi AZ, O'Donnell PD. Follow up outcome of intracavernous papaverine. J Ark Med Soc. 1990;86(10):383-385. [pmid: 2138146].
Alivizatos G, Skolarikos A, Laguna P. Recent data upon impotence, incontinence and quality of life issues concerning radical prostatectomy. [Review] [74 refs]. Arch Esp Urol. 2003;56(3):321-330. [pmid: 12768997].
Allan CA, McLachlan RI. Age-related changes in testosterone and the role of replacement therapy in older men. Clin Endocrinol (Oxf). 2004;60(6):653-670. [pmid: 15163327].
Althof SE, Cappelleri JC, Shpilsky A, et al. Treatment responsiveness of the Self-Esteem And Relationship questionnaire in erectile dysfunction. Urology. 2003;61(5):888-892. [pmid: 12735997].
Althof SE, O'Leary MP, Cappelleri JC, et al. Self-esteem, confidence, and relationships in men treated with sildenafil citrate for erectile dysfunction: results of two double-blind, placebo-controlled trials. J Gen Intern Med. 2006;21(10):1069-1074. [pmid: 16836626].
Altwein JE, Keuler FU. Oral treatment of erectile dysfunction with apomorphine SL. [Review] [34 refs]. Urol Int. 2001;67(4):257-263. [pmid: 11741126].
Anderson DC, Seifert CF. Topical nitrate treatment of impotence. [Review] [17 refs]. Ann Pharmacother. 1993;27(10):1203-1205. [pmid: 8251690].
Anderson RA, Bancroft J, Wu FC. The effects of exogenous testosterone on sexuality and mood of normal men. Journal of Clinical Endocrinology & Metabolism. 1992;75(6):1503-1507. [pmid: 1464655].
Andersson KE. Pharmacology of penile erection. Pharmacol Rev. 2001;53(3):417-450. [pmid: 11546836].
Anonymous. Sildenafil and erectile dysfunction: new preparation. Helpful. Prescrire.Int 1998;7(38):163–165.
Anonymous. Sublingual apomorphine: new preparation. In erectile disorders: a narrow therapeutic margin. Prescrire.Int 2002;11(59):76–79.
Anonymous. Vardenafil (levitra) for erectile dysfunction. Medical Letter on Drugs & Therapeutics 2003;45(1166):77–78.
Anonymous. Viagra: a blueprint for safety and reliability. Johns Hopkins Medical Letter, Health After 50 2002;14(10):4–5.
Anonymous. Vasoactive intestinal peptide/phentolamine. Invicorp, vasopotin. Drugs in R & D 1999;2(6):436–438.
Anonymous. Treatment for impotence gains FDA approval. Am J Health Syst Pharm 1995;52(19):2078–2079.
Anonymous. L-arginine. Altern Med Rev 2005;10(2):139–147.
Anonymous. Use of sildenafil for ED classes II and III. S Afr Med J 2005;95(1):38
Anonymous. Patient preference of ED drugs studied. British Journal of Diabetes &Vascular Disease 2003;3(6):444
Anonymous. New drug for erectile dysfunction. Can Pharm J 2002;268(7200):756
Anonymous. Vardenafil improves erectile function in men with diabetes. Can Pharm J 2001;267(7155):
Anonymous. Alprostadil for erectile impotence. Drug & Therapeutics Bulletin 1995;33(8):61–62.
Anonymous. What to do if Viagra won't do. Harvard Mens Health Watch 2005;9(10):4–8.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: intracavernous injection of prostaglandin E1. JAMA 1991;265(24):3321–3323.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: papaverine and phentolamine. JAMA 1990;264(6):752–754.
Aranda P, Ruilope LM, Calvo C, et al. Erectile dysfunction in essential arterial hypertension and effects of sildenafil: results of a Spanish national study. Am J Hypertens. 2004;17(2):139-145. [pmid: 14751656].
Ardicoglu A, Kocakoc E, Tuygun UO, et al. Effectiveness of vardenafil versus papaverine in penile Doppler ultrasonography. Urol Int. 2005;75(1):75-79. [pmid: 16037713].
Ardicoglu A, Kocakoc E, Yuzgec V, et al. Hemodynamic effects of sildenafil citrate (Viagra) on segmental branches of bilateral renal arteries. International Urology & Nephrology. 2005;37(4):785-789. [pmid: 16362600].
Armstrong DK, Convery AG, Dinsmore WW. Reasons for patient drop-out from an intracavernous auto-injection programme for erectile dysfunction. Br J Urol. 1994;74(1):99-101. [pmid: 8044533].
Armstrong DK, Convery A, Dinsmore WW. Prostaglandin E1 in the medical management of erectile dysfunction in a genito-urinary medicine clinic. Ulster Med J. 1994;63(1):18-22. [pmid: 8658990].
Arver S, Dobs AS, Meikle AW, et al. Improvement of sexual function in testosterone deficient men treated for 1 year with a permeation enhanced testosterone transdermal system. Br J Urol. 1996;155(5):1604-1608.
Ashok S, Sigman M. Bioavailable testosterone should be used for the determination of androgen levels in infertile men. Br J Urol. 2007;177(4):1443-1446.
Ashton Adam Keller. Yohimbine in the treatment of male erectile dysfunction. Am J Psychiatry. 1994;151(9):1397. [pmid: 8067505].
Assalian Pierre. Sildenafil for St. John wort-induced sexual dysfunction. [References]. J Sex Marital Ther. 2000;26(4):357-358. [pmid: 11056902].
Atmaca M, Kuloglu M, Tezcan E. Sildenafil use in patients with olanzapine-induced erectile dysfunction. Int J Impot Res. 2002;14(6):547-549. [pmid: 12494295].
Aukst-Margetic B, Margetic B. An open-label series using loratadine for the treatment of sexual dysfunction associated with selective serotonin reuptake inhibitors. Prog Neuropsychopharmacol Biol Psychiatry. 2005;29(5):754-756. [pmid: 15913872].
Aversa A, Bonifacio V, Moretti C, et al. Re-dosing of prostaglandin-E1 versus prostaglandin-E1 plus phentolamine in male erectile dysfunction: a dynamic color power Doppler study. Int J Impot Res. 2000;12(1):33-40. [pmid: 10982310].
Aviv A, Shelef A, Weizman A. An open-label trial of sildenafil addition in risperidone-treated male schizophrenia patients with erectile dysfunction. Hillside J Clin Psychiatry. 2004;65(1):97-103.
Ayub W, Fletcher S. End-stage renal disease and erectile dysfunction. Is there any hope?. Nephrology Dialysis Transplantation. 2000;15(10):1525-1528.
Bacar MM, Batislam E, Altinok D, et al. Sildenafil citrate for penile hemodynamic determination: an alternative to intracavernosal agents in Doppler ultrasound evaluation of erectile dysfunction. Urology. 2001;57(4):623-626. [pmid: 11306361].
Bach Amy K, Barlow David H, Wincze John PE. The enhancing effects of manualized treatment for erectile dysfunction among men using sildenafil: A preliminary investigation. [References]. Behav Ther. 2004;35(1):55-73.
Bai WJ, Zhu JC, Jiang H, et al. [A comparative study of different vasoactive drugs in the treatment of impotence]. Chinese Journal of Urology. 1992;13(6):453-455.
Bain J. Andropause. Testosterone replacement therapy for aging men. [Review] [55 refs]. Can Fam Physician. 2001;47:91-97. [pmid: 11212438].
Balon Richard. Sildenafil and sexual dysfunction associated with antidepressants. [References]. J Sex Marital Ther. 1999;25(4):259-264. [pmid: 10546162].
Balon Richard. Fluvoxamine-induced erectile dysfunction responding to sildenafil. J Sex Marital Ther. 1998;24(4):313-317. [pmid: 9805292].
Bancroft J, Gutierrez P. Erectile dysfunction in men with and without diabetes mellitus: a comparative study.[see comment]. Diabet Med. 1996;13(1):84-89. [pmid: 8741818].
Bancroft J, Smith G, Munoz M, et al. Erectile response to visual erotic stimuli before and after intracavernosal papaverine, and its relationship to nocturnal penile tumescence and psychometric assessment. Br J Urol. 1991;68(6):629-638. [pmid: 1773296].
Baniel J, Israilov S, Engelstein D, et al. Three-year outcome of a progressive treatment program for erectile dysfunction with intracavernous injections of vasoactive drugs. Urology. 2000;56(4):647-652. [pmid: 11018623].
Barrou B, Cuzin B, Malavaud B, et al. Early experience with sildenafil for the treatment of erectile dysfunction in renal transplant recipients. Nephrol Dial Transplant. 2003;18(2):411-417. [pmid: 12543900].
Beal K, Mears JG. Short report: Penile lymphoma following local injections for erectile dysfunction. Leuk Lymphoma. 2001;42(12):247-249. [pmid: 11699217].
Becher E. Topical alprostadil cream for the treatment of erectile dysfunction. [Review] [46 refs]. Expert Opin Pharmacother. 2004;5(3):623-632. [pmid: 15013930].
Behrend L, Vibe-Petersen J, Perrild H. Sildenafil in the treatment of erectile dysfunction in men with diabetes: demand, efficacy and patient satisfaction. Int J Impot Res. 2005;17(3):264-269. [pmid: 15674401].
Bell DSH, Cutter GR, Hayne VB, et al. Factors predicting efficacy of phentolamine-papaverine intracorporeal injection for treatment of erectile dysfunction in diabetic male. Urology. 1992;40(1):36-40. [pmid: 1621310].
Benatov R, Reznik I, Zemishlany Z. Sildenafil citrate (Viagra) treatment of sexual dysfunction in a schizophrenic patient. [References]. Eur Psychiatry. 1999;14(6):353-355. [pmid: 10572370].
Benchekroun A, Faik M, Benjelloun S, et al. A baseline-controlled, open-label, flexible dose-escalation study to assess the safety and efficacy of sildenafil citrate (Viagra) in patients with erectile dysfunction. Int J Impot Res. 2003;15(Suppl 1):19-24.
Benevides MD, Carson CC. Intraurethral application of alprostadil in patients with failed inflatable penile prosthesis. Br J Urol. 2000;163(3):785-787.
Beretta G, Marzotto M, Zanollo A, et al. Office treatment: intracavernous injections of prostaglandin E1 (PG E1) and improvement of spontaneous erections. Acta Eur Fertil. 1991;22(4):221-223. [pmid: 1844326].
Berner M M, Kriston L, Harms A. Efficacy of PDE-5-inhibitors for erectile dysfunction. A comparative meta-analysis of fixed-dose regimen randomized controlled trials administering the International Index of Erectile Function in broad-spectrum populations. Int J Impot Res 2005;
Billington CJ, Shafer RB, Morley JE. Effects of opioid blockade with nalmefene in older impotent men. Life Sci. 1990;47(9):799-805. [pmid: 2120527].
Bird TD, Lipe HP, Crabtree LD. Impotence associated with the Charcot-Marie-Tooth syndrome. Eur Neurol. 1994;34(3):155-157. [pmid: 8033941].
Bischoff E. Vardenafil preclinical trial data: Potency, pharmacodynamics, pharmacokinetics, and adverse events. Int J Impot Res. 2004;16(SUPPL. 1):S34-S37. [pmid: 15224134].
Black AM, Day AG, Morales A. The reliability of clinical and biochemical assessment in symptomatic late-onset hypogonadism: Can a case be made for a 3-month therapeutic trial?. BJU Int. 2004;94(7):1066-1070. [pmid: 15541129].
Blanker MH, Thomas S, Bohnen AM. Systematic review of Viagra RCTs. Br J Gen Pract. 2002;52(477):329. [pmid: 11942454].
Blonde L. Sildenafil citrate for erectile dysfunction in men with diabetes and cardiovascular risk factors: a retrospective analysis of pooled data from placebo-controlled trials. Curr Med Res Opin. 2006;22(11):2111-2120. [pmid: 17076971].
Bocchi EA, Guimaraes G, Mocelin A, et al. Sildenafil effects on exercise, neurohormonal activation, and erectile dysfunction in congestive heart failure: a double-blind, placebo-controlled, randomized study followed by a prospective treatment for erectile dysfunction. Circulation. 2002;106(9):1097-1103. [pmid: 12196335].
Bodansky HJE. Successful tadalafil treatment for erectile dysfunction associated with Charcot-Marie-Tooth syndrome. [References]. Sexual and Relationship Therapy. 2006;21(1):87-89.
Bolona ER, Uraga MV, Haddad RM, et al. Testosterone use in men with sexual dysfunction: a systematic review and meta-analysis of randomized placebo-controlled trials. Mayo Clin Proc. 2007;82(1):20-28. [pmid: 17285782].
Bouloux P. Testim 1% testosterone gel for the treatment of male hypogonadism. [Review] [33 refs]. Clin Ther. 2005;27(3):286-298. [pmid: 15878382].
Boyarsky BK, Haque W, Rouleau MR, et al. Sexual functioning in depressed outpatients taking mirtazapine. Depression & Anxiety. 1999;9(4):175-179. [pmid: 10431683].
Braatvedt GD. Outcome of managing impotence in clinical practice. N Z Med J. 1999;112(1092):272-274. [pmid: 10472891].
Brazil M. Viagra for broken hearts?. Nat Rev Genet. 2005;4(3):190.
Briganti A, Salonia A, Gallina A, et al. Drug insight: Oral phosphodiesterase type 5 inhibitors for erectile dysfunction. Nature Clinical Practice Urology. 2005;2(5):239-247.
Brignardello E, Manti R, Papotti M, et al. Ectopic secretion of LH by an endocrine pancreatic tumor. J Endocrinol Invest. 2004;27(4):361-365. [pmid: 15233557].
Brindis RG, Kloner RA. Sildenafil in patients with cardiovascular disease. [Review] [33 refs]. Am J Cardiol. 2003;92(9A):26M-36M. [pmid: 12842240].
Brisson TE, Broderick GA, Thiel DD, et al. Vardenafil rescue rates of sildenafil nonresponders: objective assessment of 327 patients with erectile dysfunction. Urology. 2006;68(2):397-401. [pmid: 16904460].
Brock GB, McMahon CG, Chen KK, et al. Efficacy and safety of tadalafil for the treatment of erectile dysfunction: results of integrated analyses. Br J Urol. 2002;168(4 Pt 1):1332-1336.
Brock G, Chan J, Carrier S, et al. The treatment of erectile dysfunction study: focus on treatment satisfaction of patients and partners. BJU Int. 2007;99(2):376-382. [pmid: 17155989].
Brown SL, Haas CA, Koehler M, et al. Hepatotoxicity related to intracavernous pharmacotherapy with papaverine. Urology. 1998;52(5):844-847. [pmid: 9801111].
Buddeberg C, Bucher T, Hornung R. [Erectile dysfunction in men in their second half of life]. Urologe 2005;Ausg. A. 44(9):1045–1046, 1048–51.
Burge MR, Lanzi RA, Skarda ST, et al. Idiopathic hypogonadotropic hypogonadism in a male runner is reversed by clomiphene citrate. Fertility & Sterility. 1997;67(4):783-785. [pmid: 9093212].
Burls A, Gold L, Clark W. Systematic review of randomised controlled trials of sildenafil (Viagra) in the treatment of male erectile dysfunction. Br J Gen Pract. 2001;51(473):1004-1012. [pmid: 11766850].
Burnett AL. Vasoactive pharmacotherapy to cure erectile dysfunction: fact or fiction?. [Review] [45 refs]. Urology. 2005;65(2):224-230. [pmid: 15708027].
Burns-Cox N, Gingell C. The andropause: fact or fiction?. [Review] [49 refs]. Postgrad Med J. 1997;73(863):553-556. [pmid: 9373594].
Buvat J. Hyperprolactinemia and sexual function in men: a short review. [Review] [26 refs]. Int J Impot Res. 2003;15(5):373-377. [pmid: 14562140].
Buvat J, Montorsi F. Safety and tolerability of apomorphine SL in patients with erectile dysfunction. BJU Int. 2001;88(3):30-35. [pmid: 11578277].
Buvat J, Lemaire A, Ratajczyk J. Acceptance, efficacy and preference of Sildenafil in patients on long term auto-intracavernosal therapy: a study with follow-up at one year. Int J Impot Res. 2002;14(6):483-486. [pmid: 12494282].
Calof OM, Singh AB, Lee ML, et al. Adverse events associated with testosterone replacement in middle-aged and older men: A meta-analysis of randomized, placebo-controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60(11):1451-1457.
Cappelleri JC, Althof SE, Siegel RL, et al. Association between the Erectile Dysfunction Inventory of Treatment Satisfaction and the Self-Esteem and Relationship Questionnaire following treatment with sildenafil citrate for men with erectile dysfunction. Value Health. 2005;8(Suppl 1):54-60.
Cappelleri JC, Bell SS, Althof SE, et al. Comparison between sildenafil-treated subjects with erectile dysfunction and control subjects on the Self-Esteem And Relationship questionnaire. Br J Sex Med. 2006;3(2):274-282.
Carani C, Granata AR, Bancroft J, et al. The effects of testosterone replacement on nocturnal penile tumescence and rigidity and erectile response to visual erotic stimuli in hypogonadal men. Psychoneuroendocrinology. 1995;20(7):743-753. [pmid: 8848520].
Carani C, Zini D, Baldini A, et al. Effects of androgen treatment in impotent men with normal and low levels of free testosterone. Arch Sex Behav. 1990;19(3):223-234. [pmid: 2193636].
Caretta N, Palego P, Ferlin A, et al. Resumption of spontaneous erections in selected patients affected by erectile dysfunction and various degrees of carotid wall alteration: Role of tadalafil. Eur Urol. 2005;48(2):326-332. [pmid: 16005378].
Carey F, Quah SP, Dinsmore W. Postal survey to determine how many patients continued to seek treatment with sildenafil following sildenafil trials. Int J STD AIDS. 2003;14(7):501-502. [pmid: 12869236].
Carey MP, Johnson BT. Effectiveness of yohimbine in the treatment of erectile disorder: four meta-analytic integrations. Arch Sex Behav. 1996;25(4):341-360. [pmid: 8836468].
Carosa E, Martini P, Brandetti F, et al. Type V phosphodiesterase inhibitor treatments for erectile dysfunction increase testosterone levels. Clin Endocrinol (Oxf). 2004;61(3):382-386. [pmid: 15355456].
Carson CC, Burnett AL, Levine LA, et al. The efficacy of sildenafil citrate (Viagra) in clinical populations: an update. Urology. 2002;60(2 Suppl 2):12-27. [pmid: 12414330].
Carson CC, Rajfer J, Eardley I, et al. The efficacy and safety of tadalafil: an update. BJU Int. 2004;93(9):1276-1281. [pmid: 15180622].
Caruso S, Intelisano G, Farina M, et al. Efficacy and safety of daily intake of apomorphine SL in men affected by erectile dysfunction and mild hyperprolactinemia: a prospective, open-label, pilot study. Urology. 2003;62(5):922-927. [pmid: 14624921].
Casella R, Deckart A, Bachmann A, et al. The patient's self-evaluation better predicts the degree of erectile dysfunction than the response to intracavernous alprostadil testing. Urol Int. 2004;72(3):216-220. [pmid: 15084765].
Chaiban JT, Azar ST. Erectile dysfunction in diabetic patients. J Med Liban. 2004;52(4):217-219. [pmid: 16432985].
Chatterjee R, Kottaridis PD, McGarrigle HH, et al. Management of erectile dysfunction by combination therapy with testosterone and sildenafil in recipients of high-dose therapy for haematological malignancies. Bone Marrow Transplant. 2002;29(7):607-610. [pmid: 11979311].
Cheitlin MD, Hutter AM, Brindis RG, et al. Use of sildenafil (Viagra) in patients with cardiovascular disease. Circulation. 1999;99(1):168-177. [pmid: 9884398].
Chen JK, Hwang TI, Yang CR. Comparison of effects following the intracorporeal injection of papaverine and prostaglandin E1. Br J Urol. 1992;69(4):404-407. [pmid: 1581812].
Chen J, Godschalk MF, Katz PG, et al. Incidence of penile pain after injection of a new formulation of prostaglandin E1.[see comment]. Br J Urol. 1995;154(1):77-79.
Chen J, Godschalk MF, Katz PG, et al. Combining intracavernous injection and external vacuum as treatment for erectile dysfunction.[see comment]. Br J Urol. 1995;153(5):1476-1477.
Chen J, Godschalk M, Katz PG, et al. The lowest effective dose of prostaglandin E1 as treatment for erectile dysfunction. Br J Urol. 1995;153(1):80-81.
Chen J, Mabjeesh NJ, Greenstein A, et al. Clinical efficacy of sildenafil in patients on chronic dialysis. Br J Urol. 2001;165(3):819-821.
Chen J, Sofer M, Kaver I, et al. Concomitant use of sildenafil and a vacuum entrapment device for the treatment of erectile dysfunction. Br J Urol. 2004;171(1):292-295.
Chen KK, Jiann BP, Lin JSN, et al. Erratum: Efficacy and safety of on- demand oral tadalafil in the treatment of men eith erectile dysfunction in Taiwan: A randomized, double- blind, parallel, placebo- conrolled clinical study (Journal of Sexual Medicine vol. 1 (2)). Br J Sex Med. 2005;2(1):158.
Cheng E. Real-life safety and efficacy of vardenafil in the treatment of erectile dysfunction-results from 30,010 U.S. patients. Br J Sex Med. 2007;4(2):432-439.
Chew KK. Prevalence of hypogonadism in the aging male and male erectile dysfunction in Asia-Pacific countries. Asian J Androl. 2003;5(2):171-172.
Chew KK, Stuckey BGA. Use of transurethral alprostadil (MUSE) (prostaglandin E1) for glans tumescence in a patient with penile prosthesis. Int J Impot Res. 2000;12(3):195-196. [pmid: 11045915].
Chew KK, Stuckey BGA, Thompson PL. Erectile dysfunction, sildenafil and cardiovascular risk. Med J Aust. 2000;172(6):279-283. [pmid: 10860094].
Chia S. Management of premature ejaculation—a comparison of treatment outcome in patients with and without erectile dysfunction. Int J Androl. 2002;25(5):301-305. [pmid: 12270028].
Chia SJ, Ramesh K, Earnest A. Clinical application of prognostic factors for patients with organic causes of erectile dysfunction on 100 mg of sildenafil citrate. Int J Urol. 2004;11(12):1104-1109. [pmid: 15663683].
Chiang HS, Wen TC, Liang JF. Titration study of MUSE (Medicated Urethral System for Erection) in erectile dysfunction. J Formos Med Assoc. 2000;99(12):926-930. [pmid: 11155746].
Chiang HS, Kao YH, Sheu MT. Papaverine and prostaglandin E1 gel applications for impotence. Ann Acad Med Singapore. 1995;24(5):767-769. [pmid: 8579329].
Chiang PH, Tsai EM, Chiang CP. The role of trazodone in the treatment of erectile dysfunction. Kao-Hsiung i Hsueh Ko Hsueh Tsa Chih [Kaohsiung Journal of Medical Sciences]. 1994;10(6):287-294.
Chinegwundoh F, Anie K A. Treatments for priapism in boys and men with sickle cell disease. [Review][16 refs]. Cochrane Database Syst Rev 2004;(4):CD004198
Choi HK, Adimoelja A, Kim SC, et al. A dose-response study of alprostadil sterile powder (S.Po.) (Caverject) for the treatment of erectile dysfunction in Korean and Indonesian men. Int J Impot Res. 1997;9(1):47-51. [pmid: 9138059].
Christ B, Brockmeier D, Hauck EW, et al. Investigation on interaction between tacrolimus and sildenafil in kidney-transplanted patients with erectile dysfunction. International Journal of Clinical Pharmacology & Therapeutics. 2004;42(3):149-156. [pmid: 15049434].
Christ GJ, Melman A. The application of gene therapy to the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):111-112. [pmid: 9647947].
Chun SS, Fenemore J, Heaton JP, et al. Enhancement of erectile responses to vasoactive drugs by a variable amplitude oscillation device. Int J Impot Res. 1996;8(4):221-225. [pmid: 8981171].
Clark C. Erectile dysfunction and other problems. Can Pharm J. 2004;272(7299):608-610.
Claro JA, Ximenes SF, Nardozza A, et al. Effect of sildenafil in cavernous arteries of patients with erectile dysfunction. International Braz J Urol. 2003;29(4):320-326. [pmid: 15745555].
Cohen JS. Comparison of FDA reports of patient deaths associated with sildenafil and with injectable alprostadil. Ann Pharmacother. 2001;35(3):285-288. [pmid: 11261524].
Conti CR, Pepine CJ, Sweeney M. Efficacy and safety of sildenafil citrate in the treatment of erectile dysfunction in patients with ischemic heart disease. Am J Cardiol. 1999;83(5A):29C-34C.
Cooper AJ. Evaluation of I-C papaverine in patients with psychogenic and organic impotence. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 1991;36(8):574-578. [pmid: 1742710].
Copel L, Katz R, Blachar A, et al. Clinical and duplex US assessment of effects of sildenafil on cavernosal arteries of the penis: Comparison with intracavernosal injection of vasoactive agents - Initial experience. Radiology. 2005;237(3):986-991. [pmid: 16237136].
Corona G, Mannucci E, Fisher AD, et al. Effect of hyperprolactinemia in male patients consulting for sexual dysfunction. Br J Sex Med. 2007;4(5):1485-1493.
Corona G, Mannucci E, Schulman C, et al. Psychobiologic correlates of the metabolic syndrome and associated sexual dysfunction. Eur Urol. 2006;50(3):595-604. [pmid: 16564129].
Costabile RA, Spevak M, Fishman IJ, et al. Efficacy and safety of transurethral alprostadil in patients with erectile dysfunction following radical prostatectomy. Br J Urol. 1998;160(4):1325-1328.
Crowe SM, Streetman DS. Vardenafil treatment for erectile dysfunction. [Review] [43 refs]. Ann Pharmacother. 2004;38(1):77-85. [pmid: 14742800].
Curran M, Keating G. Tadalafil.[erratum appears in Drugs. 2003;63(23):2703]. [Review] [31 refs]. Drugs. 2003;63(20):2203-2212. [pmid: 14498756].
Dachille G, Pagliarulo V, Ludovico GM, et al. Sexual dysfunction in patients under dialytic treatment. Minerva Urol Nefrol. 2006;58(2):195-200. [pmid: 16767073].
Davis BE, Weigel JW, Whitford CS. Treatment of male impotence: a new option. Kans Med. 1990;91(12):325-326. [pmid: 1705298].
De Rose AF, Giglio M, Traverso P, et al. Combined oral therapy with sildenafil and doxazosin for the treatment of non-organic erectile dysfunction refractory to sildenafil monotherapy. Int J Impot Res. 2002;14(1):50-53. [pmid: 11896478].
De Meyer JM, Thibo P, Hatzichriston DG. The effect of re-dosing of vasodilators on the intracavernosal pressure and on the penile rigidity. Eur Urol. 1998;33(3):293-297. [pmid: 9555555].
De Siati M, Saugo M, Franzolin N. The start of pharmacological activity after sublingual administration of sildenafil citrate in 30 patients affected by erectile dysfunction. Arch Ital Urol Androl. 2003;75(1):18-20. [pmid: 12741340].
Decter RM, Furness PD, Nguyen TA, et al. Reproductive understanding, sexual functioning and testosterone levels in men with spina bifida. Br J Urol. 1997;157(4):1466-1468.
Derby CA, Araujo AB, Johannes CB, et al. Measurement of erectile dysfunction in population-based studies: the use of a single question self-assessment in the Massachusetts Male Aging Study. Int J Impot Res. 2000;12(4):197-204. [pmid: 11079360].
Derry F, Hultling C, Seftel AD, et al. Efficacy and safety of sildenafil citrate (Viagra) in men with erectile dysfunction and spinal cord injury: a review. Urology. 2002;60(2 Suppl 2):49-57. [pmid: 12414333].
Dhabuwala CB, Kerkar P, Bhutwala A, et al. Intracavernous papaverine in the management of psychogenic impotence. Arch Androl. 1990;24(2):185-191. [pmid: 2327828].
Dinsmore WW. Medical treatment of impotence with papaverine and phentolamine intracavernosal injection. Ulster Med J. 1990;59(2):174-176. [pmid: 2278115].
Dinsmore WW, Alderdice DK. Vasoactive intestinal polypeptide and phentolamine mesylate administered by autoinjector in the treatment of patients with erectile dysfunction resistant to other intracavernosal agents. Br J Urol. 1998;81(3):437-440. [pmid: 9523666].
Dizon MN, Vesely DL. Gonadotropin-secreting pituitary tumor associated with hypersecretion of testosterone and hypogonadism after hypophysectomy. Endocr Pract. 2002;8(3):225-231. [pmid: 12113637].
Doggrell SA. Comparison of clinical trials with sildenafil, vardenafil and tadalafil in erectile dysfunction. Expert Opin Pharmacother. 2005;6(1):75-84. [pmid: 15709885].
Donatucci CF, Lue TF. Erectile dysfunction in men under 40: etiology and treatment choice. Int J Impot Res. 1993;5(2):97-103. [pmid: 8348217].
Donatucci C, Eardley I, Buvat J, et al. Vardenafil improves erectile function in men with erectile dysfunction irrespective of disease severity and disease classification. Br J Sex Med. 2004;1(3):301-309.
Dundar SO, Dayanir Y, Topalolu A, et al. Effect of sildenafil on ocular hemodynamics in 3 months regular use. Int J Impot Res. 2006;18(3):282-286. [pmid: 16292333].
Dundar SO, Topalolu A, Dundar M, et al. Effects of sildenafil on blue-on-yellow and white-on-white Humphrey perimetry in 3 months regular use. Arb Paul Ehrlich Inst Georg Speyer Haus Ferdinand Blum Inst Frankf A M. 2006;20(7):810-813.
Dunn A. Sildenafil: A new therapy for erectile dysfunction. Conn Med. 1998;62(7):413-416. [pmid: 9707795].
Dusing R. Effect of the angiotensin II antagonist valsartan on sexual function in hypertensive men. Blood Pressure Supplement. 2003;2:29-34. [pmid: 14761074].
Eardley I. New oral therapies for the treatment of erectile dysfunction. Br J Urol. 1998;81(1):122-127. [pmid: 9467488].
El Malik EMA. Erectile dysfunction: An update of diagnosis and management. Qatar Medical Journal. 2000;9(2):9-17.
El-Sakka AI. Efficacy of sildenafil citrate in treatment of erectile dysfunction: effect of type 2 diabetes. Eur Urol. 2004;46(4):503-509. [pmid: 15363568].
El-Sakka AI. Efficacy of sildenafil citrate in treatment of erectile dysfunction: impact of associated premature ejaculation and low desire. Urology. 2006;68(3):642-647. [pmid: 16979718].
El-Sakka AI, Hassoba HM, Elbakry AM, et al. Prostatic specific antigen in patients with hypogonadism: Effect of testosterone replacement. Br J Sex Med. 2005;2(2):235-240.
Elhanbly S, Schoor R, Elmogy M, et al. What nonresponse to intracavernous injection really indicates: a determination by quantitative analysis. Br J Urol. 2002;167(1):192-196.
Engel JD, McVary KT. Transurethral alprostadil as therapy for patients who withdrew from or failed prior intracavernous injection therapy. Urology. 1998;51(5):687-692. [pmid: 9610580].
Engelhardt PF, Daha LK, Zils T, et al. Acupuncture in the treatment of psychogenic erectile dysfunction: first results of a prospective randomized placebo-controlled study. Int J Impot Res. 2003;15(5):343-346. [pmid: 14562135].
Engelhardt PF, Plas E, Hubner WA, et al. Comparison of intraurethral liposomal and intracavernosal prostaglandin-E1 in the management of erectile dysfunction. Br J Urol. 1998;81(3):441-444. [pmid: 9523667].
Engl T, Beecken WD, Wolfram M, et al. Uropharmacology: Current and future strategies in the treatment of erectile dysfunction and benign prostate hyperplasia. International Journal of Clinical Pharmacology & Therapeutics. 2004;42(10):527-533. [pmid: 15516021].
English JC, King DHC, Foley JP. Penile shaft hypopigmentation: Lichen sclerosus occurring after the initiation of alprostadil intracavernous injections for erectile dysfunction. J Am Acad Dermatol. 1998;39(5 I):801-803. [pmid: 9810901].
Erbagci A, Yagci F, Sarica K, et al. Evaluation and therapeutic regulation of erectile dysfunction with visual stimulation test. An objective approach by using sildenafil citrate test. Urol Int. 2002;69(1):21-26. [pmid: 12119434].
Erdogru T, Usta MF, Ceken K, et al. Is sildenafil citrate an alternative agent in the evaluation of penile vascular system with color Doppler ultrasound?. Urol Int. 2002;68(4):255-260. [pmid: 12053028].
Ernst E, Pittler MH. Yohimbine for erectile dysfunction: a systematic review and meta-analysis of randomized clinical trials. J Urol. 1998;159(2):433-436. [pmid: 9649257].
Escobar-Jimenez F. [Efficacy and safety of sildenafil in men with type 2 diabetes mellitus and erectile dysfunction]. Med Clin (Barc). 2002;119(4):121-124. [pmid: 12106522].
Espinoza R, Melchor JL, Gracida C. Sildenafil (Viagra) in kidney transplant recipients with erectile dysfunction. Transplant Proc. 2002;34(1):408-409. [pmid: 11959347].
Fagelman E, Fagelman A, Shabsigh R. Efficacy, safety, and use of sildenafil in urologic practice. Urology. 2001;57(6):1141-1144. [pmid: 11377328].
Fava M, Rankin MA, Alpert JE, et al. An open trial of oral sildenafilin antidepressant-induced sexual dysfunction. Psychotherapy & Psychosomatics. 1998;67(6):328-331. [pmid: 9817955].
Fazeli-Matin S, Montague DK, Angermeier KW, et al. Penile fracture after intracavernous injection therapy. Br J Urol. 1998;159(6):2094.
Fedele D, Coscelli C, Cucinotta D, et al. Management of erectile dysfunction in diabetic subjects: results from a survey of 400 diabetes centres in Italy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14(5):277-282.
Fein RL. Classification of sexual dysfunction for management of intracavernous medication-induced erections.[see comment]. Br J Urol. 1990;143(2):298-301.
Feldman R, Meuleman EJ, Steers W. Sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction: analysis of two flexible dose-escalation studies. Sildenafil Study Group. Int J Clin Pract. 1999;102(Suppl Jun.):100-102.
Fink HA, Mac Donald R, Rutks IR, et al. Sildenafil for male erectile dysfunction: a systematic review and meta-analysis. Arch Intern Med. 2002;162(12):1349-1360. [pmid: 12076233].
Fink HA, MacDonald R, Rutks IR, et al. Trazodone for erectile dysfunction: a systematic review and meta-analysis. BJU Int. 2003;92(4):441-446. [pmid: 12930437].
Fishbain David A. Impact of sildenafil on male erectile disorder due to psychological factors. Can J Psychiatry. 2000;45(1):85-86. [pmid: 10696497].
Flack JM. The effect of doxazosin on sexual function in patients with benign prostatic hyperplasia, hypertension, or both.[see comment]. [Review] [47 refs]. Int J Clin Pract. 2002;56(7):527-530. [pmid: 12296615].
Fonseca V, Seftel A, Denne J, et al. Impact of diabetes mellitus on the severity of erectile dysfunction and response to treatment: analysis of data from tadalafil clinical trials. Diabetologia. 2004;47(11):1914-1923. [pmid: 15599697].
Foresta C, Caretta N, Lana A, et al. Relationship Between Vascular Damage Degrees and Endothelial Progenitor Cells in Patients with Erectile Dysfunction: Effect of Vardenafil Administration and PDE5 Expression in the Bone Marrow. Eur Urol. 2007;51(5):1411-1419. [pmid: 17034932].
Foresta C, Ferlin A, De Toni L, et al. Circulating endothelial progenitor cells and endothelial function after chronic Tadalafil treatment in subjects with erectile dysfunction. Int J Impot Res. 2006;18(5):484-488. [pmid: 16541115].
Foulks CJ, Cushner HM. Sexual dysfunction in the male dialysis patient: pathogenesis, evaluation, and therapy. [Review] [105 refs]. Am J Kidney Dis. 1986;8(4):211-222. [pmid: 3532769].
Fox KM, Thadani U, Ma PT, et al. Sildenafil citrate does not reduce exercise tolerance in men with erectile dysfunction and chronic stable angina. Eur Heart J. 2003;24(24):2206-2212. [pmid: 14659772].
Freitas D, Athanazio R, Almeida D, et al. Sildenafil improves quality of life in men with heart failure and erectile dysfunction. Int J Impot Res. 2006;18(2):210-212. [pmid: 16121207].
Fugl-Meyer AR, Lodnert G, Branholm IB, et al. On life satisfaction in male erectile dysfunction. Int J Impot Res. 1997;9(3):141-148. [pmid: 9315491].
Fugl-Meyer KS, Stothard D, Belger M, et al. The effect of tadalafil on psychosocial outcomes in Swedish men with erectile distress: a multicentre, non-randomised, open-label clinical study. Int J Clin Pract. 2006;60(11):1386-1393. [pmid: 17073836].
Fujisawa M, Sawada K. Clinical efficacy and safety of sildenafil in elderly patients with erectile dysfunction. Arch Androl. 2004;50(4):255-260. [pmid: 15277003].
Fulgham PF, Cochran JS, Denman JL, et al. Disappointing initial results with transurethral alprostadil for erectile dysfunction in a urology practice setting. Br J Urol. 1998;160(6 Pt 1):2041-2046.
Gana TE, Quizanos LF, Castell R, et al. A dose-response study of alprostadil in patients with erectile dysfunction. Curr Ther Res Clin Exp. 1996;57(9):700-710.
Garcia-Bravo AM, Suarez-Hernandez D, Ruiz-Fernandez MA, et al. Determination of changes in blood pressure during administration of sildenafil (Viagra) in patients with spinal cord injury and erectile dysfunction. Proc Annu Clin Spinal Cord Inj Conf. 2006;44(5):301-308.
Ghanem H, Sherif T, bdEl-Gawad T, et al. Short term use of intracavernous vasoactive drugs in the treatment of persistent psychogenic erectile dysfunction. Int J Impot Res. 1998;10(4):211-214. [pmid: 9884916].
Gheorghiu S, Godschalk M, Gentili A, et al. Quality of life in patients using self-administered intracavernous injections of prostaglandin E1 for erectile dysfunction. Br J Urol. 1996;156(1):80-81.
Giammusso B, Morgia G, Spampinato A, et al. Improved pallesthetic sensitivity of pudendal nerve in impotent diabetic patients treated with acetyl-L-carnitine. Acta Urologica Italica. 1996;10(3):185-187.
Gil A, Martinez E, Oyaguez I, et al. Erectile dysfunction in a primary care setting: results of an observational, no-control-group, prospective study with sildenafil under routine conditions of use. Int J Impot Res. 2001;13(6):338-347. [pmid: 11918250].
Gilbert HW, Gingell JC. The results of an intracorporeal papaverine clinic. Sex Marital Ther. 1991;6(1):49-56.
Gilbert HW, Gillatt DA, Desai KM, et al. Intracorporeal papaverine injection in androgen deprived men. J R Soc Med. 1990;83(3):161. [pmid: 2182861].
Gilbert R N, Graham C W, Regan J B. Double-blind- cross-over trial of testosterone enanthate in impotent men with low or low-normal serum testosterone levels. Br J Urol 1992;147264
Gillies HC, Roblin D, Jackson G. Coronary and systemic hemodynamic effects of sildenafil citrate: From basic science to clinical studies in patients with cardiovascular disease. Int J Cardiol. 2002;86(23):131-141. [pmid: 12419549].
Gingell C, Buvat J, Jardin A et al. Sildenafil citrate (VIAGRA(TM)), an oral treatment for erectile function: 1-year, open-label, extension studies. Int J Clin Pract 1999;(pp 30–31):-31.
Ginsberg DL. Vardenafil treatment of sertraline-induced sexual dysfunction. Primary Psychiatry. 2004;11(11):23-24.
Ginsberg David L. Sildenafil-dihydrocodeine interaction results in prolonged erections. [References]. Primary Psychiatry. 2003;10(2):23.
Ginzburg R, Wong Y, Fader JS. Effect of bupropion on sexual dysfunction. Ann Pharmacother. 2005;39(12):2096-2099. [pmid: 16288071].
Giuliano F, Donatucci C, Montorsi F, et al. Vardenafil is effective and well-tolerated for treating erectile dysfunction in a broad population of men, irrespective of age. BJU Int. 2005;95(1):110-116. [pmid: 15638906].
Giuliano F, Montorsi F, Mirone V, et al. Switching from intracavernous prostaglandin E1 injections to oral sildenafil citrate in patients with erectile dysfunction: results of a multicenter European study. The Sildenafil Multicenter Study Group. Br J Urol. 2000;164(3:Pt 1):t-11.
Giuliano F, Pena BM, Mishra A, et al. Efficacy results and quality-of-life measures in men receiving sildenafil citrate for the treatment of erectile dysfunction. Qual Life Res. 2001;10(4):359-369. [pmid: 11763248].
Giuliano F, Rubio-Aurioles E, Kennelly M, et al. Efficacy and safety of vardenafil in men with erectile dysfunction caused by spinal cord injury. Neurology. 2006;66(2):210-216. [pmid: 16434656].
Glenn DRJ, McClure N, Lewis SEM. The hidden impact of diabetes on male sexual dysfunction and fertility. Hum Fertil. 2003;6(4):174-179.
Glina S, Sotomayor M, Gatchalian E, et al. Timing of dose relative to sexual intercourse attempt in previous sildenafil citrate users treated with tadalafil. Br J Sex Med. 2006;3(2):309-319.
Godschalk MF, Chen J, Katz PG, et al. Prostaglandin E1 as treatment for erectile failure in elderly men. J Am Geriatr Soc. 1994;42(12):1263-1265. [pmid: 7983289].
Godschalk M, Gheorghiu D, Chen J, et al. Long-term efficacy of a new formulation of prostaglandin E1 as treatment for erectile failure. Br J Urol. 1996;155(3):915-917.
Gogtay NJ, Bichile SK, Pinto CJ, et al. Erectile dysfunction and sildenafil citrate.[comment]. J Assoc Physicians India. 2001;49:871-872. [pmid: 11837751].
Goldenberg MM. Safety and efficacy of sildenafil citrate in the treatment of male erectile dysfunction. Clin Ther. 1998;20(6):1033-1048. [pmid: 9916601].
Goldstein I. Oral phentolamine: an alpha-1, alpha-2 adrenergic antagonist for the treatment of erectile dysfunction. [Review][9 refs]. Int J Impot Res 2000;12Suppl-80.
Goldstein I. A 36-week, open label, non-comparative study to assess the long-term safety of sildenafil citrate (VIAGRA) in patients with erectile dysfunction. Int J Clin Pract 1999;Supplement.102–109.
Goldstein I, Auerbach S, Padma-Nathan H, et al. Axial penile rigidity as primary efficacy outcome during multi-institutional in-office dose titration clinical trials with alprostadil alfadex in patients with erectile dysfunction. Alprostadil Alfadex Study Group. Int J Impot Res. 2000;12(4):205-211. [pmid: 11079361].
Goldstein I, Kim E, Steers WD, et al. Efficacy and safety of tadalafil in men with erectile dysfunction with a high prevalence of comorbid conditions: results from MOMENTUS: multiple observations in men with erectile dysfunction in National Tadalafil Study in the US. Br J Sex Med. 2007;4(1):166-175.
Gomery P, Bullock A, McGettigan J, et al. Tadalafil is efficacious in Black American and Hispanic men with erectile dysfunction: results from multiple observations in men with erectile dysfunction in national tadalafil study in the US (MOMENTUS). Int J Impot Res. 2007;19(1):76-83. [pmid: 16728966].
Goonawardena SA, de Silva WA, Ketheeswaran T. Pharmacologically induced penile erections in the assessment and treatment of erectile impotence: a preliminary study of 100 patients. Ceylon Med J. 1997;42(2):72-74. [pmid: 9257465].
Gore JL, Swerdloff RS, Rajfer J. Androgen deficiency in the etiology and treatment of erectile dysfunction. Urol Clin North Am. 2005;32(4):457-468. [pmid: 16291037].
Govier FE, McClure RD, Weissman RM, et al. Experience with triple-drug therapy in a pharmacological erection program.[see comment]. Br J Urol. 1993;150(6):1822-1824.
Greco EA, Pili M, Bruzziches R, et al. Testosterone:estradiol ratio changes associated with long-term tadalafil administration: a pilot study. Br J Sex Med. 2006;3(4):716-722.
Greco E, Polonio-Balbi P. Penile rigidity in erectile dysfunction treated with alprostadil. Lancet. 1997;350(9092):1682. [pmid: 9400524].
Greco E, Balbi PP, Virag R. Self intra-cavernous injections as a successful treatment in pure neurogenic impotence. Riv Neurol. 1991;61(1):35-38. [pmid: 1857921].
Green BG, Martin S. Clinical assessment of sildenafil in the treatment of neurogenic male sexual dysfunction: After the hype. NeuroRehabilitation. 2000;15(2):101-105. [pmid: 11455087].
Greenstein A, Mabjeesh NJ, Sofer M, et al. Does sildenafil combined with testosterone gel improve erectile dysfunction in hypogonadal men in whom testosterone supplement therapy alone failed?[see comment]. Br J Urol. 2005;173(2):530-532.
Gresser U, Gleiter CH. Erectile dysfunction: comparison of efficacy and side effects of the PDE-5 inhibitors sildenafil, vardenafil and tadalafil—review of the literature. [Review] [92 refs]. Eur J Med Res. 2002;7(10):435-446. [pmid: 12435622].
Gross AJ, Sauerwein DH, Kutzenberger J, et al. Penile prostheses in paraplegic men. Br J Urol. 1996;78(2):262-264. [pmid: 8813925].
Grossman EB, Swan SK, Muirhead GJ, et al. The pharmacokinetics and hemodynamics of sildenafil citrate in male hemodialysis patients. Kidney Int. 2004;66(1):367-374. [pmid: 15200445].
Grover JK, Vats V, Ajeeta. Sildenafil (Viagra(TM)). Medico-Legal Update. 1998;3(12):67-78.
Guay AT, Perez JB, Jacobson J, et al. Efficacy and safety of sildenafil citrate for treatment of erectile dysfunction in a population with associated organic risk factors.[erratum appears in J Androl 2002 Jan-Feb;23(1):113]. J Androl. 2001;22(5):793-797. [pmid: 11545291].
Guay AT, Perez JB, Velasquez E, et al. Clinical experience with intraurethral alprostadil (MUSE) in the treatment of men with erectile dysfunction. A retrospective study. Medicated urethral system for erection. Eur Urol. 2000;38(6):671-676. [pmid: 11111182].
Guay AT, Spark RF, Jacobson J, et al. Yohimbine treatment of organic erectile dysfunction in a dose-escalation trial. Int J Impot Res. 2002;14(1):25-31. [pmid: 11896474].
Gupta N, Sawlani K K, Tripathi AK. Appropriate use of sildenafil citrate in male erectile dysfunction.[see comment]. [Review] [52 refs]. J Assoc Physicians India. 2001;49:889-896. [pmid: 11837756].
Gupta Sanjay, Masand Prakash, Ashton Adam K, et al. Phenelzine-induced sexual dysfunction treated with sildenafil. J Sex Marital Ther. 1999;25(2):131-135. [pmid: 10327382].
Gutierrez P, Hernandez P, Mas M. Combining programmed intracavernous PGE1 injections and sildenafil on demand to salvage sildenafil nonresponders. Int J Impot Res. 2005;17(4):354-358. [pmid: 15703770].
Hammadeh MY, Madaan S, Hines J, et al. 5-year outcome of a prospective randomized trial to compare transurethral electrovaporization of the prostate and standard transurethral resection. Urology. 2003;61(6):1166-1171. [pmid: 12809891].
Harding LM, Adeniyi A, Everson R, et al. Comparison of a needle-free high-pressure injection system with needle-tipped injection of intracavernosal alprostadil for erectile dysfunction. Int J Impot Res. 2002;14(6):498-501. [pmid: 12494285].
Harrold LR, Gurwitz JH, Field TS, et al. The diffusion of a novel therapy into clinical practice: the case of sildenafil.[see comment]. Arch Intern Med. 2000;160(22):3401-3405. [pmid: 11112232].
Harwood PJ, Grotz M, Eardley I, et al. Erectile dysfunction after fracture of the pelvis. Journal of Bone & Joint Surgery - British Volume. 2005;87(3):281-290.
Hatzichristou D G. Sildenafil citrate: lessons learned from 3 years of clinical experience. [Review][60 refs]. Int J Impot Res 2002;14Suppl-52.
Hatzichristou D G. Current treatment and future perspectives for erectile dysfunction. [Review][85 refs]. Int J Impot Res 1998;10Suppl-13.
Hatzichristou DG, Apostolidis A, Tzortzis V, et al. Sildenafil versus intracavernous injection therapy: efficacy and preference in patients on intracavernous injection for more than 1 year. Br J Urol. 2000;164(4):1197-1200.
Hatzichristou D, Vardi Y, Papp G, et al. Effect of tadalafil on sexual timing behavior patterns in men with erectile dysfunction: integrated analysis of randomized, placebo controlled trials. Br J Urol. 2005;174(4 Pt 1):1356-1359.
Hatzimouratidis K, Hatzichristou D. Phosphodiesterase Type 5 Inhibitors: The Day After. Eur Urol. 2007;51(1):75-89. [pmid: 16949200].
Hatzimouratidis K, Hatzichristou DG. A comparative review of the options for treatment of erectile dysfunction: Which treatment for which patient?. Drugs. 2005;65(12):1621-1650. [pmid: 16060698].
Hauck E W, Altinkilic B M, Schroeder-Printzen I et al. Prostaglandin E1 long-term self-injection programme for treatment of erectile dysfunction—a follow-up of at least 5 years. Andrologia 1999;31(Suppl):Suppl-103.
He XQ, Hong BF, Wang XX, et al. Evaluation of efficacy and safety of oral sildenafil citrate therapy for men with erectile dysfunction. Pharmaceutical Journal of Chinese Peoples Liberation Army. 2002;18(4):205-208.
Heaton JP. Key issues from the clinical trials of apomorphine SL. World J Urol. 2001;19(1):25-31. [pmid: 11289567].
Heaton JPW, Wagner Porst, Eid Wyllie. Apomorphine: An update of clinical trial results. Int J Impot Res. 2000;12(SUPPL. 4):S67-S73. [pmid: 11035390].
Heaton JP, Lording D, Liu SN, et al. Intracavernosal alprostadil is effective for the treatment of erectile dysfunction in diabetic men. Int J Impot Res. 2001;13(6):317-321. [pmid: 11918246].
Heaton JP, Morales A, Adams MA, et al. Recovery of erectile function by the oral administration of apomorphine. Urology. 1995;45(2):200-206. [pmid: 7855966].
Hellstrom WJ. Vardenafil: a new approach to the treatment of erectile dysfunction. [Review] [37 refs]. Curr Urol Rep. 2003;4(6):479-487. [pmid: 14622502].
Hirsch IH, Schanne FJ, Carsello J, et al. Sequential penile ultrasound monitoring of patients treated with chronic intracavernous prostaglandin E1. Urology. 1995;45(6):1037-1041. [pmid: 7771005].
Hirsch IH, Smith RL, Chancellor MB, et al. Use of intracavernous injection of prostaglandin E1 for neuropathic erectile dysfunction. Paraplegia. 1994;32(10):661-664. [pmid: 7831071].
Hollander JB, Gonzalez J, Norman T. Patient satisfaction with pharmacologic erection program. Urology. 1992;39(5):439-441. [pmid: 1580034].
Holmes S. Tadalafil: a new treatment for erectile dysfunction. BJU Int. 2003;91(6):466-468. [pmid: 12656894].
Hong EK, Lepor H, McCullough AR. Time dependent patient satisfaction with sildenafil for erectile dysfunction (ED) after nerve-sparing radical retropubic prostatectomy (RRP). Int J Impot Res. 1999;11(SUPPL. 1):S15-S22. [pmid: 10554925].
Hong JH, Ahn TY. Oral testosterone replacement in Korean patients with PADAM. Aging Male. 2002;5(1):52-56. [pmid: 12040976].
Hookes J. Asian Federation of Medicinal Chemistry (AFMC) - Fifth International Medicinal Chemistry Symposium: 14–17 October 2003, Kyoto, Japan. IDrugs. 2003;6(11):1013-1015. [pmid: 15270004].
Huang ST, Hsieh ML. Different hemodynamic responses by color Doppler ultrasonography studies between sildenafil non-responders and responders. Asian J Androl. 2007;9(1):129-133. [pmid: 17187164].
Hubler J, Szanto A, Konyves K. Methylene blue as a means of treatment for priapism caused by intracavernous injection to combat erectile dysfunction. International Urology & Nephrology. 2003;35(4):519-521. [pmid: 15198160].
Hwang TI, Chen HE, Tsai TF, et al. Combined use of androgen and sildenafil for hypogonadal patients unresponsive to sildenafil alone. Int J Impot Res. 2006;18(4):400-404. [pmid: 16395321].
Incrocci L, Hop WC, Slob AK. Visual erotic and vibrotactile stimulation and intracavernous injection in screening men with erectile dysfunction: a 3 year experience with 406 cases. Int J Impot Res. 1996;8(4):227-232. [pmid: 8981172].
Irwin MB, Kata EJ. High attrition rate with intracavernous injection of prostaglandin E1 for impotency. Urology. 1994;43(1):84-87. [pmid: 8284888].
Isidori AM, Giannetta E, Gianfrilli D, et al. Effects of testosterone on sexual function in men: results of a meta-analysis. Clin Endocrinol (Oxf). 2005;63(4):381-394. [pmid: 16181230].
Ismail M, Abbott L, Hirsch IH. Experience with intracavernous PGE-1 in the treatment of erectile dysfunction: dose considerations and efficacy. Int J Impot Res. 1997;9(1):39-42. [pmid: 9138057].
Israilov S, Niv E, Livne PM, et al. Intracavernous injections for erectile dysfunction in patients with cardiovascular diseases and failure or contraindications for sildenafil citrate. Int J Impot Res. 2002;14(1):38-43. [pmid: 11896476].
Israilov S, Shmuely J, Niv E, et al. Evaluation of a progressive treatment program for erectile dysfunction in patients with diabetes mellitus. Int J Impot Res. 2005;17(5):431-436. [pmid: 15889124].
Jackson G. Sildenafil (Viagra): New data, new confidence in treating erectile dysfunction in the cardiovascular patient. Int J Clin Pract. 2002;56(2):75. [pmid: 11926708].
Jackson G, Keltai M, Csanady M, et al. Hemodynamic effects of sildenafil citrate and isosorbide mononitrate in men with coronary artery disease and erectile dysfunction. Br J Sex Med. 2005;2(3):407-414.
Jackson G, Kloner RA, Costigan TM, et al. Update on clinical trials of tadalafil demonstrates no increased risk of cardiovascular adverse events. Br J Sex Med. 2004;1(2):161-167.
Jackson G, Montorsi P, Cheitlin MD. Cardiovascular safety of sildenafil citrate (Viagra): an updated perspective. [Review] [52 refs]. Urology. 2006;68(3 Suppl):47-60. [pmid: 17011375].
Jacobsen FM. Fluoxetine-induced sexual dysfunction and an open trial of yohimbine.[see comment]. Hillside J Clin Psychiatry. 1992;53(4):119-122.
Jain P, Rademaker AW, McVary KT. Testosterone supplementation for erectile dysfunction: results of a meta-analysis. Br J Urol. 2000;164(2):371-375.
Jarow JP, Burnett AL, Geringer AM. Clinical efficacy of sildenafil citrate based on etiology and response to prior treatment.[see comment]. Br J Urol. 1999;162(3:Pt 1):t-5.
Jiann BP, Yu CC, Su CC, et al. Rechallenge prior sildenafil nonresponders. Int J Impot Res. 2004;16(1):64-68. [pmid: 14963473].
Jiann BP, Yu CC, Tsai JY, et al. What to learn about sildenafil in the treatment of erectile dysfunction from 3-year clinical experience. Int J Impot Res. 2003;15(6):412-417. [pmid: 14671659].
Jiann BP, Yu CC, Su CC. Impact of introduction of sildenafil on other treatment modalities for erectile dysfunction: A study of nationwide and local hospital sales. Int J Impot Res. 2004;16(6):527-530. [pmid: 15229626].
John H, Lehmann K, Hauri D. Intraurethral prostaglandin improves quality of vacuum erection therapy. Eur Urol. 1996;29(2):224-226. [pmid: 8647152].
Juergense PH, Botev R, Wuerth D, et al. Erectile dysfunction in chronic peritoneal dialysis patients: incidence and treatment with sildenafil. Perit Dial Int. 2001;21(4):355-359. [pmid: 11587397].
Kadioglu A, Erdogru T, Tellaloglu S. Combined intracavernous injection of papaverine and stimulation (CIS) test. J Androl. 1994;15(Suppl):50S-53S. [pmid: 7721678].
Kaplan B, Ben-Rafael Z, Peled Y, et al. Oral sildenafil may reverse secondary ejaculatory dysfunction during infertility treatment. Fertility & Sterility. 1999;72(6):1144-1145. [pmid: 10593398].
Kaplan Helen S. The combined use of sex therapy and intrapenile injections in the treatment of impotence. J Sex Marital Ther. 1990;16(4):195-207. [pmid: 2079703].
Kaplan SA, Reis RB, Kohn IJ, et al. Combination therapy using oral alpha-blockers and intracavernosal injection in men with erectile dysfunction. Urology. 1998;52(5):739-743. [pmid: 9801091].
Karabulut A, Peskircioglu L, Ozkardes H, et al. Objective penile vascular response to intraurethral prostaglandin E2 (dinoprostone). Urol Int. 2001;67(2):160-162. [pmid: 11490212].
Kassouf W, Carrier S. A comparison of the International Index of Erectile Function and erectile dysfunction studies. BJU Int. 2003;91(7):667-669. [pmid: 12699481].
Katlowitz NM, Albano GJ, Morales P, et al. Potentiation of drug-induced erection with audiovisual sexual stimulation. Urology. 1993;41(5):431-434. [pmid: 8488610].
Katlowitz N, Albano GJ, Patsias G, et al. Effect of multidose intracorporeal injection and audiovisual sexual stimulation in vasculogenic impotence. Urology. 1993;42(6):695-697. [pmid: 8256402].
Kattan SA. The acceptance of satisfaction of Saudi males to vasoactive autoinjection intracavernous therapy, external negative pressure device and penile prosthesis in the treatment of erectile dysfunction. Ann Saudi Med. 2002;22(34):149-152. [pmid: 17159384].
Kaufman JM, Hatzichristou DG, Mulhall JP, et al. Impotence and chronic renal failure: a study of the hemodynamic pathophysiology. Br J Urol. 1994;151(3):612-618.
Keating GM, Scott LJ. Vardenafil: a review of its use in erectile dysfunction. Drugs. 2003;63(23):2673-2703. [pmid: 14636086].
Keating GM, Scott LJ. Spotlight on vardenafil in erectile dysfunction. Drugs Aging. 2004;21(2):135-140. [pmid: 14960129].
Kedia S, Zippe CD, Agarwal A, et al. Treatment of erectile dysfunction with sildenafil citrate (Viagra) after radiation therapy for prostate cancer. Urology. 1999;54(2):308-312. [pmid: 10443730].
Kendirci M, Bivalacqua TJ, Hellstrom WJ. Vardenafil: a novel type 5 phosphodiesterase inhibitor for the treatment of erectile dysfunction. Expert Opin Pharmacother. 2004;5(4):923-932. [pmid: 15102574].
Khan MA, Raistrick M, Mikhailidis DP, et al. MUSE: clinical experience. Current Medical Research & Opinion. 2002;18(2):64-67. [pmid: 12017211].
Khan MM, Khwaja M. Open label study of intracavernous injection of alpostadil alphadex in the treatment of erectile dysfunction. J Postgrad Med Inst. 2005;19(1):52-57.
Kim ED, McVary KT. Topical prostaglandin-E1 for the treatment of erectile dysfunction. Br J Urol. 1995;153(6):1828-1830.
Kim ED, el-Rashidy R, McVary KT. Papaverine topical gel for treatment of erectile dysfunction. Br J Urol. 1995;153(2):361-365.
Kim JM, Joh YD, Huh JD, et al. Doppler sonography of the penile cavernosal artery: comparison of intraurethral instillation and intracorporeal injection of prostaglandin E1. J Clin Ultrasound. 2001;29(5):273-278. [pmid: 11486321].
Kim NN, Christianson DW, Traish AM. Role of arginase in the male and female sexual arousal response. Br J Nutr. 2004;134(10 SUPPL.):2873S-2879S.
Kim SC, Ahn TY, Choi HK, et al. Multicenter study of the treatment of erectile dysfunction with transurethral alprostadil (MUSE) in Korea. Int J Impot Res. 2000;12(2):97-101. [pmid: 11052635].
Kim SC, Chang IH, Jeon HJ. Preference for oral sildenafil or intracavernosal injection in patients with erectile dysfunction already using intracavernosal injection for > 1 year. BJU Int. 2003;92(3):277-280. [pmid: 12887483].
Kim SC, Lee SW, Seo KK. Characteristics of pain following intracavernous injection of prostaglandin E1. J Korean Med Sci. 1997;12(4):327-331. [pmid: 9288633].
Kloner RA. Cardiovascular risk and sildenafil. [Review] [27 refs]. Am J Cardiol. 2000;86(2A):57F-61F.
Kloner RA, Zusman RM. Cardiovascular effects of sildenafil citrate and recommendations for its use. [Review] [21 refs]. Am J Cardiol. 1999;84(5B):11N-17N.
Kloner RA, Brown M, Prisant LM, et al. Effect of sildenafil in patients with erectile dysfunction taking antihypertensive therapy. Sildenafil Study Group. Am J Hypertens. 2001;14(1):70-73. [pmid: 11206684].
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil in patients on common antihypertensive therapies. [Review] [5 refs]. Am J Cardiol. 2003;92(9A):47M-57M. [pmid: 12842244].
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil. [Review] [12 refs]. Am J Cardiol. 2003;92(9A):37M-46M.
Kloner RA, Sadovsky R, Johnson EG, et al. Efficacy of tadalafil in the treatment of erectile dysfunction in hypertensive men on concomitant thiazide diuretic therapy. Int J Impot Res. 2005;17(5):450-454. [pmid: 16015377].
Kloner RA, Sadovsky R, Johnson EG, et al. Efficacy of tadalafil in the treatment of erectile dysfunction in hypertensive men on concomitant thiazide diuretic therapy. Br J Urol. 2006;175(4):1450.
Knispel HH. Penile venous surgery in impotence: results in highly selected cases. Urol Int. 1991;47(3):144-148. [pmid: 1771702].
Knispel HH, Huland H. Influence of cause on choice of therapy in 174 patients with erectile dysfunction. Br J Urol. 1992;147(5):1274-1276.
Koksal M, Ozdemir H, Kargi S, et al. The effects of sildenafil on ocular blood flow. Acta Ophthalmol Scand. 2005;83(3):355-359. [pmid: 15948790].
Kongkanand A, Opanuraks J, Tantiwongse K, et al. Evaluating dose regimens of apomorphine, an open-label study. Int J Impot Res. 2003;15(Suppl 2):10-12. [pmid: 12605235].
Kongkanand A, Ratana-Olarn K, Wuddhikarn S, et al. Evaluation of transurethal alprostadil for safety and efficacy in men with erectile dysfunction. J Med Assoc Thai. 2002;85(2):223-228. [pmid: 12081123].
Kramer-Levien D J. Papaverine—the medical implant. AUAA J 1987;7(4):13-Jun.
Kriston L, Harms A, Berner MM. A meta-regression analysis of treatment effect modifiers in trials with flexible-dose oral sildenafil for erectile dysfunction in broad-spectrum populations. Int J Impot Res. 2006;18(6):559-565. [pmid: 16688210].
Kromann-Andersen B. Intracavernosal pharmacotherapy with injection pen. Lancet. 1988;1(85756):54-59. [pmid: 2891913].
Kuba R, Pohanka M, Zakopcan J, et al. Sexual dysfunctions and blood hormonal profile in men with focal epilepsy. Epilepsia. 2006;47(12):2135-2140. [pmid: 17201714].
Kunelius P, Lukkarinenl O. Intracavernous self-injection of prostaglandin E1 in the treatment of erectile dysfunction. Int J Impot Res. 1999;11(1):21-24. [pmid: 10098949].
Kuzmarov IW, Ross D, Skamene A, et al. A sexual tune-up program as an adjunct to intracavernous pharmacotherapy. Can J Hum Sex. 1993;2(4):239-241.
Labbate Lawrence A, Grimes Jamie B, Hines Alan, et al. Bupropion treatment of serotonin reuptake antidepressant-associated sexual dysfunction. Ann Clin Psychiatry. 1997;9(4):241-245. [pmid: 9511948].
Lakin MM, Montague DK, VanderBrug Medendorp S, et al. Intracavernous injection therapy: Analysis of results and complications. Br J Urol. 1990;143(6):1138-1141.
Lal S, Kiely ME, Thavundayil JX, et al. Effect of bromocriptine in patients with apomorphine-responsive erectile impotence: an open study. J Psychiatry Neurosci. 1991;16(5):262-266. [pmid: 1797100].
Lance R, Albo M, Costabile RA, et al. Oral trazodone as empirical therapy for erectile dysfunction: a retrospective review. Urology. 1995;46(1):117-120. [pmid: 7604472].
Lane BZ, Ausmundson SJ, Butler RS, et al. Use of a visual analog scale to assess pain of injection with intracavernous injection therapy. Br J Sex Med. 2005;2(3):428-431.
Laties A, Sharlip I. Ocular safety in patients using sildenafil citrate therapy for erectile dysfunction. [Review] [81 refs]. Br J Sex Med. 2006;3(1):12-27.
Laties AM, Zrenner E. Viagra (sildenafil citrate) and ophthalmology. Progress in Retinal & Eye Research. 2002;21(5):485-506. [pmid: 12207947].
Laties A M, Fraunfelder F T, Flach A J et al. Ocular safety of Viagra, (sildenafil citrate). Trans Am Ophthalmol Soc 1999;97(pp 115–128):-128.
Lawless C, Cree J. Oral medications in the management of erectile dysfunction. [Review] [15 refs]. J Am Board Fam Pract. 1998;11(4):307-314. [pmid: 9719353].
Lawless C, Force RW. Sildenafil for erectile dysfunction. J Fam Pract. 1998;47(2):97-98. [pmid: 9722794].
Lawrence IG, Price DE, Howlett TA, et al. Correcting impotence in the male dialysis patient: experience with testosterone replacement and vacuum tumescence therapy. Am J Kidney Dis. 1998;31(2):313-319. [pmid: 9469503].
Le Bon O, Lion K, Verbanck P, et al. Fluparoxan in male erectile disorder: A case report. Yakubutsu Seishin Kodo. 1995;9(1):67-68.
Lea AP, Bryson HM, Balfour JA. Intracavernous alprostadil. A review of its pharmacodynamic and pharmacokinetic properties and therapeutic potential in erectile dysfunction. [Review] [123 refs]. Drugs Aging. 1996;8(1):56-74. [pmid: 8785470].
Lee J, Pommerville P, Brock G, et al. Physician-rated patient preference and patient- and partner-rated preference for tadalafil or sildenafil citrate: results from the Canadian ‘Treatment of Erectile Dysfunction’ observational study. BJU Int. 2006;98(3):623-629. [pmid: 16925764].
Lee W R. The role of androgen deprivation therapy combined with prostate brachytherapy. [Review][31 refs]. Urology 2002;60(3:Suppl 1):Suppl-44.
Levine LA, Latchamsetty KC. Treatment of erectile dysfunction in patients with Peyronie's disease using sildenafil citrate. Int J Impot Res. 2002;14(6):478-482. [pmid: 12494281].
Levitt EE, Mulcahy JJ. The effect of intracavernosal injection of papaverine hydrochloride on orgasm latency. Br J Sex Med. 1995;21(1):39-42.
Lewis RL, Sadovsky R, Eardley I, et al. The efficacy of tadalafil in clinical populations. Br J Sex Med. 2005;2(4):517-531.
Lewis RW. Intraurethral and topical agents. Med Actual. 2000;36(23):113-119.
Li MK, Lim PH, Wong MY, et al. Transurethral alprostadil for the treatment of erectile dysfunction: results of a multicentre trial. Ann Acad Med Singapore. 2000;29(6):727-731. [pmid: 11269978].
Lim PH, Ng FC. Erectile dysfunction in Singapore men: presentation, diagnosis, treatment and results. Ann Acad Med Singapore. 1992;21(2):248-253. [pmid: 1519896].
Lim PHC, Man KL, Foo CN, et al. Clinical efficacy and safety of sildenafil citrate (Viagra) in a multi-racial population in Singapore: A retrospective study of 1520 patients. Int J Urol. 2002;9(6):308-315. [pmid: 12110094].
Liu LC, Wu CC, Liu LH, et al. Comparison of the effects of papaverine versus prostaglandin E1 on penile blood flow by color duplex sonography. Eur Urol. 1991;19(1):49-53. [pmid: 2007418].
Livi U, Faggian G, Sorbara C, et al. Use of prostaglandin E1 in the treatment of sexual impotence after heart transplantation: initial clinical experience. Journal of Heart & Lung Transplantation. 1993;12(3):484-486. [pmid: 8329422].
Lombardo T, Giammusso B, Frontini V, et al. Thalassaemic men affected by erectile dysfunction treated with transurethral alprostadil: case report. Hum Reprod. 2000;15(11):2375-2378. [pmid: 11056136].
Long RL, Sherman LS, Lombardi TJ. A goal-oriented, cost-effective approach to the diagnosis and treatment of 24 male erectile dysfunction. [Review] [24 refs]. J Ky Med Assoc. 1995;93(11):500-508. [pmid: 8778212].
Lottman PE, Hendriks JC, Vruggink PA, et al. The impact of marital satisfaction and psychological counselling on the outcome of ICI-treatment in men with ED. Int J Impot Res. 1998;10(2):83-87. [pmid: 9647943].
Lowentritt BH, Scardino PT, Miles BJ, et al. Sildenafil citrate after radical retropubic prostatectomy. Br J Urol. 1999;162(5):1614-1617.
Lowy M, Collins S, Bloch M, et al. Quality of erection questionnaire correlates: change in erection quality with erectile function, hardness, and psychosocial measures in men treated with sildenafil for erectile dysfunction. Br J Sex Med. 2007;4(1):83-92.
Lue TF. Impotence after radical pelvic surgery: physiology and management. [Review] [56 refs]. Urol Int. 1991;46(3):259-265. [pmid: 1926639].
Lukkarinen O, Tonttila P, Hellstrom P, et al. Non-prosthetic surgery in the treatment of erectile dysfunction. A retrospective study of 45 impotent patients in the University of Oulu. Scandinavian Journal of Urology & Nephrology. 1998;32(1):42-46. [pmid: 9561573].
Lundberg L, Olsson JO, Kihl B. Long-term experience of self-injection therapy with prostaglandin E1 for erectile dysfunction. Scand J Urol Nephrol. 1996;30(5):395-397. [pmid: 8936629].
Lunenfeld B. Androgen therapy in the aging male. [Review] [110 refs]. World J Urol. 2003;21(5):292-305. [pmid: 14576959].
Magoha GA. Sildenafil (Viagra) in the treatment of male erectile dysfunction in Nairobi. East Afr Med J. 2000;77(2):76-79. [pmid: 10774079].
Manecke RG, Mulhall JP. Medical treatment of erectile dysfunction. [Review] [69 refs]. Ann Med. 1999;31(6):388-398. [pmid: 10680853].
Maniam P, Seftel AD, Corty EW, et al. Nocturnal penile tumescence activity unchanged after long-term intracavernous injection therapy. Br J Urol. 2001;165(3):830-832.
Mansi MK, Alkhudair WK, Huraib S. Treatment of erectile dysfunction after kidney transplantation with intracavernosal self-injection of prostaglandin E1. Br J Urol. 1998;159(6):1927-1930.
Marberger M, Roehrborn CG, Marks LS, et al. Relationship among serum testosterone, sexual function, and response to treatment in men receiving dutasteride for benign prostatic hyperplasia. Journal of Clinical Endocrinology & Metabolism. 2006;91(4):1323-1328. [pmid: 16434455].
Mark SD, Keane TE, Vandemark RM, et al. Impotence following pelvic fracture urethral injury: incidence, aetiology and management. Br J Urol. 1995;75(1):62-64. [pmid: 7850299].
Markou S, Perimenis P, Gyftopoulos K, et al. Vardenafil (Levitra) for erectile dysfunction: a systematic review and meta-analysis of clinical trial reports. Int J Impot Res. 2004;16(6):470-478. [pmid: 15229625].
Marks LS, Duda C, Dorey FJ, et al. Treatment of erectile dysfunction with sildenafil.[see comment]. Urology. 1999;53(1):19-24. [pmid: 9886582].
Marshall GA, Breza J, Lue TF. Improved hemodynamic response after long-term intracavernous injection for impotence. Urology. 1994;43(6):844-848. [pmid: 8197648].
Martin-Morales A, Haro JM, Beardsworth A, et al. Therapeutic effectiveness and patient satisfaction after 6 months of treatment with tadalafil, sildenafil, and vardenafil: results from the erectile dysfunction observational study (EDOS). Eur Urol. 2007;51(2):541-550. [pmid: 17084518].
Martin-Morales A, Moncada Iribarren I, Cruz Navarro N, et al. [Efficacy and safety of two dosing regimens with Tadalafil in Spanish men with erectile dysfunction: results from the SURE study in 14 European countries]. Actas Urol Esp. 2006;30(8):791-800. [pmid: 17078576].
Martinez R, Puigvert A, Pomerol JM, et al. Clinical experience with apomorphine hydrochloride: the first 107 patients. Br J Urol. 2003;170(6:Pt 1):t-5.
Martinez-Jabaloyas JM, Gil-Salom M, Villamon-Fort R, et al. Prognostic factors for response to sildenafil in patients with erectile dysfunction. Eur Urol. 2001;40(6):641-647. [pmid: 11805410].
Martinez-Pineiro L, Cortes R, Cuervo E, et al. Prospective comparative study with intracavernous sodium nitroprusside and prostaglandin E1 in patients with erectile dysfunction. Eur Urol. 1998;34(4):350-354. [pmid: 9748684].
Matthew AG, Goldman A, Trachtenberg J, et al. Sexual dysfunction after radical prostatectomy: Prevalence, treatments, restricted use of treatments and distress. Br J Urol. 2005;174(6):2105-2110.
Maytom MC, Derry FA, Dinsmore WW, et al. A two-part pilot study of sildenafil (VIAGRA) in men with erectile dysfunction caused by spinal cord injury. Spinal Cord. 1999;37(2):110-116. [pmid: 10065749].
McClure RD. Endocrine evaluation and therapy of erectile dysfunction. [Review] [77 refs]. Urol Clin North Am. 1988;15(1):53-64. [pmid: 3278476].
McClure RD, Oses R, Ernest ML. Hypogonadal impotence treated by transdermal testosterone. Urology. 1991;37(3):224-228. [pmid: 2000678].
McConnell JD, Roehrborn CG, Bautista OM, et al. The Long-Term Effect of Doxazosin, Finasteride, and Combination Therapy on the Clinical Progression of Benign Prostatic Hyperplasia. N Engl J Med. 2003;349(25):2387-2398. [pmid: 14681504].
McCullough AR, Barada JH, Fawzy A, et al. Achieving treatment optimization with sildenafil citrate (Viagra) in patients with erectile dysfunction. Urology. 2002;60(2 Suppl 2):28-38. [pmid: 12414331].
McCullough AR, Carson CC, Hatzichristou D. A prospective study of the beneficial effects of dose optimization and customized instructions on patient satisfaction with sildenafil citrate (Viagra) for erectile dysfunction. Urology. 2006;68(3 Suppl):38-46. [pmid: 17011374].
McMahon C. Comparison of erectile responses to differing doses of prostaglandin PGE1 in an attempt to standardise pharmacological diagnosis of impotence. Journal of Assisted Reproduction & Genetics 1992;9265A
McMahon C. Efficacy and safety of daily tadalafil in men with erectile dysfunction previously unresponsive to on-demand tadalafil. Br J Sex Med. 2004;1(3):292-300.
McMahon CG. High dose sildenafil citrate as a salvage therapy for severe erectile dysfunction. Int J Impot Res. 2002;14(6):533-538. [pmid: 12494291].
McMahon CG. An attempt to standardize the pharmacological diagnostic screening of vasculogenic impotence with prostaglandin E1. Int J Impot Res. 1995;7(2):83-90. [pmid: 7496445].
McMahon CG. Topiglan: MacroChem. Curr Opin Investig Drugs. 2002;3(4):602-606.
McMahon CG. A pilot study of the role of intracavernous injection of vasoactive intestinal peptide (VIP) and phentolamine mesylate in the treatment of erectile dysfunction. Int J Impot Res. 1996;8(4):233-236. [pmid: 8981173].
McMahon CG. Priapism associated with concurrent use of phosphodiesterase inhibitor drugs and intracavernous injection therapy. Int J Impot Res. 2003;15(5):383-384. [pmid: 14562142].
McMahon CG, Samali R, Johnson H. Efficacy, safety and patient acceptance of sildenafil citrate as treatment for erectile dysfunction. Br J Urol. 2000;164(4):1192-1196.
McMahon CG, Samali R, Johnson H. Treatment of intracorporeal injection nonresponse with sildenafil alone or in combination with triple agent intracorporeal injection therapy. Br J Urol. 1997;162(6):1992-1997.
McMahon C, Lording D, Stuckey B, et al. Vardenafil improved erectile function in a "real-life" broad population study of men with moderate to severe erectile dysfunction in Australia and New Zealand. Br J Sex Med. 2006;3(5):892-900.
McVary KT, Polepalle S, Riggi S, et al. Topical prostaglandin E1 SEPA gel for the treatment of erectile dysfunction. Br J Urol. 1999;162(3 Pt 1):732.
Mealy NE. Alprostadil cream. Drugs of the Future. 2004;29(6):626-627.
Mealy NE, Bayes M. PT-141. Drugs of the Future. 2004;29(11):1177.
Mehdiyev T V. Intracavernous injection probe of vasoactive preparations in the diagnosis of erectile dysfunctions in patients with diabetes mellitus. Azerbaidzhanskii Meditsinskii Zhurnal 2002;(pp 17–19):-19.
Meinhardt W, de la, Fuente RB, et al. Prostaglandin E1 with phentolamine for the treatment of erectile dysfunction. Int J Impot Res. 1996;8(1):5-7. [pmid: 8735187].
Meinhardt W, Nijeholt AA, Kropman RF, et al. Comparison of a mixture of papaverine, phentolamine and prostaglandin E1 with other intracavernous injections. Eur Urol. 1994;26(4):319-321. [pmid: 7713130].
Mellinger BC, Fried JJ, Darracott Vaughan. Papaverine-induced penile blood flow acceleration in impotent men measured by duplex scanning. Br J Urol. 1990;144(4):897-899.
Merrick GS, Butler WM, Lief JH, et al. Efficacy of sildenafil citrate in prostate brachytherapy patients with erectile dysfunction. Urology. 1999;53(6):1112-1116. [pmid: 10367837].
Metawea B, El-Nashar AR, Gad-Allah A, et al. Intracavernous papaverine/phentolamine-induced priapism can be accurately predicted with color Doppler ultrasonography. Urology. 2005;66(4):858-860. [pmid: 16230153].
Meyhoff HH, Rosenkilde P, Bodker A. Non-invasive management of impotence with transcutaneous nitroglycerin. Br J Urol. 1992;69(1):88-90. [pmid: 1737261].
Mikhail N. Does Testosterone Have a Role in Erectile Function?. Am J Med. 2006;119:373-382. [pmid: 16651047].
Millard RJ, Stricker PD, Lynch WJ, et al. Risks of self-injection therapy for impotence. Med J Aust. 1996;165(2):117-118. [pmid: 8692055].
Miller N, Smolkin ME, Bissonette E, et al. Undetectable prostate specific antigen at 6–12 months: a new marker for early success in hormonally treated patients after prostate brachytherapy. Cancer. 2005;103(12):2499-2506. [pmid: 15852361].
Mills TM, Lewis RW. The role of androgens in the erectile response: A 1999 perspective. Mol Urol. 1999;3(2):75-80. [pmid: 10851308].
Mirone VG, Stief CG. Efficacy of apomorphine SL in erectile dysfunction.[erratum appears in BJU Int 2002 Jan;89(1):140]. [Review] [11 refs]. BJU Int. 2001;88(Suppl 3):25-29. [pmid: 11578276].
Mirone V, Imbimbo C, Fabrizio F, et al. Ketanserin plus prostaglandin E1 (PGE-1) as intracavernosal therapy for patients with erectile dysfunction unresponsive to PGE-1 alone. Br J Urol. 1996;77(5):736-739. [pmid: 8689122].
Mirone V, Palmieri A, Cucinotta D, et al. Flexible-dose vardenafil in a community-based population of men affected by erectile dysfunction: a 12-week open-label, multicenter trial. Br J Sex Med. 2005;2(6):842-847.
Mittleman MA, Glasser DB, Orazem J. Clinical trials of sildenafil citrate (Viagra) demonstrate no increase in risk of myocardial infarction and cardiovascular death compared with placebo. Int J Clin Pract. 2003;57(7):597-600. [pmid: 14529061].
Mittleman MA, Maclure M, Glasser DB. Evaluation of acute risk for myocardial infarction in men treated with sildenafil citrate. Am J Cardiol. 2005;96(3):443-446. [pmid: 16054479].
Moemen MN, Hamed HA, Kamel II, et al. Clinical and sonographic assessment of the side effects of intracavernous injection of vasoactive substances. Int J Impot Res. 2004;16(2):143-145. [pmid: 15014552].
Moncada I, Jara J, Subira D, et al. Efficacy of sildenafil citrate at 12 hours after dosing: re-exploring the therapeutic window. Eur Urol. 2004;46(3):357-360. [pmid: 15306108].
Montorsi F, Althof SE. Partner responses to sildenafil citrate (Viagra) treatment of erectile dysfunction. Urology. 2004;63(4):762-767. [pmid: 15072897].
Montorsi F, McCullough A. Efficacy of sildenafil citrate in men with erectile dysfunction following radical prostatectomy: A systematic review of clinical data. Br J Sex Med. 2005;2(5):658-667.
Montorsi F, Althof SE, Sweeney M, et al. Treatment satisfaction in patients with erectile dysfunction switching from prostaglandin E(1) intracavernosal injection therapy to oral sildenafil citrate. Int J Impot Res. 2003;15(6):444-449. [pmid: 14671665].
Montorsi F, Briganti A, Salonia A, et al. Can Phosphodiesterase Type 5 Inhibitors Cure Erectile Dysfunction?. Eur Urol. 2006;49(6):979-986. [pmid: 16431013].
Montorsi F, Guazzoni G, Barbieri L, et al. The effect of intracorporeal injection plus genital and audiovisual sexual stimulation versus second injection on penile color Doppler sonography parameters. Br J Urol. 1996;155(2):536-540.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Effectiveness and safety of multidrug intracavernous therapy for vasculogenic impotence. Urology. 1993;42(5):554-558. [pmid: 7694416].
Montorsi F, Guazzoni G, Bergamaschi F, et al. Four-drug intracavernous therapy for impotence due to corporeal veno-occlusive dysfunction. Br J Urol. 1993;149(5 Pt 2):1291-1295.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Intracavernous vasoactive pharmacotherapy: the impact of a new self-injection device.[see comment]. Br J Urol. 1993;150(6):1829-1832.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Clinical reliability of multi-drug intracavernous vasoactive pharmacotherapy for diabetic impotence. Acta Diabetol Lat. 1994;31(1):1-5.
Montorsi F, Hellstrom WJ, Valiquette L, et al. Vardenafil provides reliable efficacy over time in men with erectile dysfunction. Urology. 2004;64(6):1187-1195. [pmid: 15596195].
Montorsi F, Perani D, Anchisi D, et al. Apomorphine-induced brain modulation during sexual stimulation: a new look at central phenomena related to erectile dysfunction. Int J Impot Res. 2003;15(3):203-209. [pmid: 12904807].
Montorsi F, Salonia A, Briganti A, et al. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol. 2005;47(5):612-621. [pmid: 15826752].
Montorsi F, Verheyden B, Meuleman E, et al. Long-term safety and tolerability of tadalafil in the treatment of erectile dysfunction. Eur Urol. 2004;45(3):339-344. [pmid: 15036680].
Moore R A, Derry S, McQuay H J. Indirect comparison of interventions using published randomised trials: systematic review of PDE-5 inhibitors for erectile dysfunction. [Review][77 refs]. BMC Urol 2005;518
Moore R A, Edwards J E, McQuay H J. Sildenafil (Viagra) for male erectile dysfunction: a meta-analysis of clinical trial reports. BMC Urol. 2002;26
Morales A, Gingell C, Collins M, et al. Clinical safety of oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):69-73. [pmid: 9647940].
Morales A, Johnston B, Heaton JP, et al. Testosterone supplementation for hypogonadal impotence: assessment of biochemical measures and therapeutic outcomes. Br J Urol. 1997;157(3):849-854.
Morales A, Johnston B, Heaton JW, et al. Oral androgens in the treatment of hypogonadal impotent men.[see comment]. Br J Urol. 1994;152(4):1115-1118.
Morgentaler A, Barada J, Niederberger C, et al. Efficacy and safety of tadalafil across ethnic groups and various risk factors in men with erectile dysfunction: Use of a novel noninferiority study design. Br J Sex Med. 2006;3(3):492-503.
Mulhall JP. Deciphering erectile dysfunction drug trials. [Review] [35 refs]. Br J Urol. 2003;170(2 Pt 1):353-358.
Mulhall JP. Sublingual apomorphine for the treatment of erectile dysfunction. [Review] [22 refs]. Expert Opin Investig Drugs. 2002;11(2):295-302.
Mulhall JP, Bukofzer S, Edmonds AL, et al. An open-label, uncontrolled dose-optimization study of sublingual apomorphine in erectile dysfunction. Clin Ther. 2001;23(8):1260-1271. [pmid: 11558862].
Mulhall JP, Guhring P, Parker M, et al. Assessment of the impact of sildenafil citrate on lower urinary tract symptoms in men with erectile dysfunction. Br J Sex Med. 2006;3(4):662-667.
Mulhall JP, Jahoda AE, Ahmed A, et al. Analysis of the consistency of intraurethral prostaglandin E(1) (MUSE) during at-home use. Urology. 2001;58(2):262-266. [pmid: 11489714].
Mulhall JP, Jahoda AE, Cairney M, et al. The causes of patient dropout from penile self-injection therapy for impotence. Br J Urol. 1999;162(4):1291-1294.
Mulhall JP, Jahoda A, Aviv N, et al. The impact of sildenafil citrate on sexual satisfaction profiles in men with a penile prosthesis in situ. BJU Int. 2004;93(1):97-99. [pmid: 14678377].
Mulhall JP, Land S, Parker M, et al. The use of an erectogenic pharmacotheraphy regimen following radical prostatectomy improves recovery of spontaneous erectile function. Br J Sex Med. 2005;2(4):532-542.
Mulhall JP, Levine LA, Junemann KP. Erection hardness: a unifying factor for defining response in the treatment of erectile dysfunction. [Review] [37 refs]. Urology. 2006;68(3 Suppl):17-25. [pmid: 17011372].
Mulhall J, Barnas J, Aviv N, et al. Sildenafil citrate response correlates with the nature and the severity of penile vascular insufficiency. Br J Sex Med. 2005;2(1):104-108.
Muller MJ, Benkert O. Lower self-reported depression in patients with erectile dysfunction after treatment with sildenafil. J Affect Disord. 2001;66(23):255-261. [pmid: 11578679].
Muller MJ, Ruof J, Graf-Morgenstern M, et al. Quality of partnership in patients with erectile dysfunction after sildenafil treatment. Pharmacopsychiatry. 2001;34(3):91-95. [pmid: 11434405].
Murat Basar M, Tekdogan UY, Yilmaz E, et al. The efficacy of sildenafil in different etiologies of erectile dysfunction. International Urology & Nephrology. 2001;32(3):403-407. [pmid: 11583361].
Murphy AM, O'Leary M. Failure of the Ambicor inflatable penile prosthesis to deflate. Int J Impot Res. 2005;17(3):291-292. [pmid: 15605073].
Murphy JC, Srinivas S, Terris MK. Flutamide administration at 500 mg daily has similar effects on serum testosterone to 750 mg daily. J Androl. 2004;25(4):630-634. [pmid: 15223852].
Mydlo JH, Viterbo R, Crispen P. Use of combined intracorporal injection and a phosphodiesterase-5 inhibitor therapy for men with a suboptimal response to sildenafil and/or vardenafil monotherapy after radical retropubic prostatectomy. BJU Int. 2005;95(6):843-846. [pmid: 15794795].
Mydlo JH, Volpe MA, MacChia RJ. Results from different patient populations using combined therapy with alprostadil and sildenafil: predictors of satisfaction. BJU Int. 2000;86(4):469-473. [pmid: 10971274].
Nagai A, Kusumi N, Tsuboi H, et al. Intracavernous injection of prostaglandin E1 is effective in patients with erectile dysfunction not responding to phosphodiseterase 5 inhibitors. Acta Med Okayama. 2005;59(6):279-280. [pmid: 16418771].
Nalesnik JG, Jones L, Kraus SR. Group B streptococcal septicemia following intracavernous injection therapy for erectile dysfunction in diabetes. Br J Urol. 2004;172(1):151-152.
Nandipati K, Raina R, Agarwal A, et al. Early combination therapy: intracavernosal injections and sildenafil following radical prostatectomy increases sexual activity and the return of natural erections. Int J Impot Res. 2006;18(5):446-451. [pmid: 16482200].
Naude JH, Le Roux PJ. Topical treatment of erectile dysfunction did not show results.[comment]. BMJ. 1998;316(7140):1318. [pmid: 9554911].
Nehra A, Blute ML, Barrett DM, et al. Rationale for combination therapy of intraurethral prostaglandin E(1) and sildenafil in the salvage of erectile dysfunction patients desiring noninvasive therapy. Int J Impot Res. 2002;14(Suppl 1):38-42. [pmid: 11896476].
Nessel Mark A. Yohimbine and pentoxifylline in the treatment of erectile dysfunction. Am J Psychiatry. 1994;151(3):453.
Nurnberg H G, Hensley P L. Sildenafil citrate for the management of antidepressant-associated erectile dysfunction. Hillside J Clin Psychiatry 2003;64Suppl-5.
Nurnberg HG, Fava M, Gelenberg AJ, et al. Open-label sildenafil treatment of partial and non-responders to double-blind treatment in men with antidepressant-associated sexual dysfunction. Int J Impot Res. 2007;19(2):167-175. [pmid: 16871270].
Nurnberg HG, Gelenberg A, Hargreave TB, et al. Efficacy of sildenafil citrate for the treatment of erectile dysfunction in men taking serotonin reuptake inhibitors. Am J Psychiatry. 2001;158(11):1926-1928. [pmid: 11691705].
Nurnberg HG, Lauriello J, Hensley PL, et al. Sildenafil for iatrogenic serotonergic antidepressant medication-induced sexual dysfunction in 4 patients.[see comment]. Hillside J Clin Psychiatry. 1999;60(1):33-35.
Nurnberg HG, Seidman SN, Gelenberg AJ, et al. Depression, antidepressant therapies, and erectile dysfunction: clinical trials of sildenafil citrate (Viagra) in treated and untreated patients with depression. Urology. 2002;60(2 Suppl 2):58-66. [pmid: 12414334].
Nurnberg H, George Hensley, Paula L, et al. Sildenafil in the treatment of sexual dysfunction induced by selective serotonin reuptake inhibitors: An overview. [References]. CNS Drugs. 2000;13(5):321-335.
O'Sullivan JD, Hughes AJ. Apomorphine-induced penile erections in Parkinson's disease. Mov Disord. 1998;13(3):536-539. [pmid: 9613749].
Ochiai A, Naya Y, Soh J, et al. Efficacy of sildenafil as the first-step therapeutic tool for Japanese patients with erectile dysfunction. Int J Impot Res. 2005;17(4):339-342. [pmid: 15829991].
Ogura K, Ichioka K, Terada N, et al. Role of sildenafil citrate in treatment of erectile dysfunction after radical retropubic prostatectomy. Int J Urol. 2004;11(3):159-163. [pmid: 15009364].
Ohebshalom M, Mulhall JP. Transdermal and topical pharmacotherapy for male sexual dysfunction. Expert Opinion on Drug Delivery. 2005;2(1):115-120. [pmid: 16296739].
Ohebshalom M, Parker M, Guhring P, et al. The efficacy of sildenafil citrate following radiation therapy for prostate cancer: temporal considerations. Br J Urol. 2005;174(1):258-262.
Opsomer RJ, Wese FX, De Groote P, et al. The external vacuum device in the management of erectile dysfunction. Acta Urol Belg. 1997;65(4):13-16. [pmid: 9497591].
Ormrod D, Easthope SE, Figgitt DP. Vardenafil.[erratum appears in Drugs Aging 2002;19(11):886]. [Review] [30 refs]. Drugs Aging. 2002;19(3):217-227. [pmid: 12027779].
Osegbe D N, Shittu O B, Aghaji A E et al. Sildenafil citrate (Viagra) for the treatment of erectile dysfunction in Nigerian men. Int J Impot Res 2003;15Suppl-8.
Osterloh IH, Riley A. Clinical update on sildenafil citrate. [Review] [58 refs]. Br J Clin Pharmacol. 2002;53(3):219-223. [pmid: 11874383].
Osterloh I H, Collins M, Wicker P et al. Sildenafil citrate (VIAGRA): overall safety profile in 18 double-blind, placebo controlled, clinical trials. [Review][0 refs]. Int J Clin Pract 1999;Supplement.102–105.
Padma-Nathan H, Yeager JL. An integrated analysis of alprostadil topical cream for the treatment of erectile dysfunction in 1732 patients. Urology. 2006;68(2):386-391. [pmid: 16904458].
Padma-Nathan H, Goldstein I, Klimberg I, et al. Long-term safety and efficacy of oral phentolamine mesylate (Vasomax) in men with mild to moderate erectile dysfunction. Int J Impot Res. 2002;14(4):266-270. [pmid: 12152116].
Padma-Nathan H, McMurray JG, Pullman WE, et al. On-demand IC351 (Cialis) enhances erectile function in patients with erectile dysfunction. Int J Impot Res. 2001;13(1):2-9. [pmid: 11313831].
Padma-Nathan H, Montorsi F, Giuliano F, et al. Vardenafil restores erectile function to normal range in men with erectile dysfunction. Br J Sex Med. 2007;4(1):152-161.
Pagani E, Glina S, Puech-Leao P, et al. Anxiety and high plasma catecholamines do not impair pharmaco-induced erection of psychogenic erectile dysfunctional patients. Int J Impot Res. 2003;15(4):282-286. [pmid: 12934057].
Pagani E, Puech-Leao P, Glina S, et al. The value of a second injection on the pharmaco-induced erection test. Int J Impot Res. 1997;9(3):167-168. [pmid: 9315495].
Pallas James, Levine Stephen B, Althof Stanley E, et al. A study using Viagra in a mental health practice. [References]. J Sex Marital Ther. 2000;26(1):41-50. [pmid: 10693115].
Palumbo F, Bettocchi C, Selvaggi FP, et al. Sildenafil: efficacy and safety in daily clinical experience. Eur Urol. 2001;40(2):176-180. [pmid: 11528195].
Pangkahila WI. Evaluation of transurethral application of alprostadil for erectile dysfunction in Indonesians. Asian J Androl. 2000;2(3):233-236. [pmid: 11225984].
Park K, Ku JH, Kim SW, et al. Risk factors in predicting a poor response to sildenafil citrate in elderly men with erectile dysfunction. BJU Int. 2005;95(3):366-370. [pmid: 15679795].
Parkerson George RJ, Willke Richard J, Hays Ron D. An international comparison of the reliability and responsiveness of the Duke Health Profile for measuring health-related quality of life of patients treated with alprostadil for erectile dysfunction. Med Care. 1999;37(1):56-67. [pmid: 10413393].
Penninga E, Jensen BA, Hansen PB, et al. Anagrelide treatment in 52 patients with chronic myeloproliferative diseases. Clinical & Laboratory Haematology. 2004;26(5):335-340. [pmid: 15485463].
Perimenis P, Athanasopoulos A, Geramoutsos I, et al. The incidence of pharmacologically induced priapism in the diagnostic and therapeutic management of 685 men with erectile dysfunction. Urol Int. 2001;66(1):27-29. [pmid: 11150947].
Perimenis P, Athanasopoulos A, Papathanasopoulos P, et al. Gabapentin in the management of the recurrent, refractory, idiopathic priapism. Int J Impot Res. 2004;16(1):84-85. [pmid: 14963477].
Perimenis P, Markou S, Gyftopoulos K, et al. Switching from long-term treatment with self-injections to oral sildenafil in diabetic patients with severe erectile dysfunction. Eur Urol. 2002;41(4):387-391. [pmid: 12074808].
Pescatori ES, Calpista A, Artibani W, et al. Self-injection devices for intracavernosal pharmacotherapy: operational classification and safety considerations. Int J Impot Res. 1996;8(2):53-57. [pmid: 8858390].
Peskircioglu L, Tekin MI, Demirag A, et al. Evaluation of erectile function in renal transplant recipients. Transplant Proc. 1998;30(3):747-749. [pmid: 9595082].
Peterson CA, Bennett AH, Hellstrom WJ, et al. Erectile response to transurethral alprostadil, prazosin and alprostadil-prazosin combinations. Br J Urol. 1998;159(5):1523-1527.
Petrov VI, Vekel'yan AS, Martyushev AV, et al. Impaza and Sildenafil: Comparison of Clinical Effectiveness in Patients with Erectile Dysfunction. Bull Exp Biol Med. 2003;135–136(Suppl 1):150-151.
Petty R, Angwin R. How real is the male menopause?. Br J Gen Pract. 2004;248(1659):452-456.
Pierce LJ, Whittington R, Hanno PM, et al. Pharmacologic erection with intracavernosal injection for men with sexual dysfunction following irradiation: a preliminary report. Int J Radiat Oncol Biol Phys. 1991;21(5):1311-1314. [pmid: 1938529].
Pohanka M, Kanovsky P, Bares M, et al. The long-lasting improvement of sexual dysfunction in patients with advanced, fluctuating Parkinson's disease induced by pergolide: evidence from the results of an open, prospective, one-year trial. Parkinsonism Relat Disord. 2005;11(8):509-512. [pmid: 15994112].
Pohanka M, Kanovsky P, Bares M, et al. Pergolide mesylate can improve sexual dysfunction in patients with Parkinson's disease: the results of an open, prospective, 6-month follow-up. Eur J Neurol. 2004;11(7):483-488. [pmid: 15257688].
Polak K, Wimpissinger B, Berisha F, et al. Effects of sildenafil on retinal blood flow and flicker-induced retinal vasodilatation in healthy subjects. Invest Ophthalmol Vis Sci. 2003;44(11):4872-4876. [pmid: 14578411].
Pomara G, Morelli G, Montorsi F, et al. Re: Montorsi F, Salonia A, Briganti A, Barbieri L, Zanni G, Surdi N, Cestari A, Montorsi P, Rigatti P. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol 2005;47:612–21 (multiple letters). Eur Urol. 2005;48(2):345-346. [pmid: 15939526].
Pomara G, Morelli G, Pomara S, et al. Cardiovascular parameter changes in patients with erectile dysfunction using pde-5 inhibitors: a study with sildenafil and vardenafil. J Androl. 2004;25(4):625-629. [pmid: 15223851].
Pommerville P. Drug treatments for erectile dysfunction: An update. Geriatrics and Aging. 2004;7(6):10-16.
Porst H. IC351 (tadalafil, Cialis): update on clinical experience. [Review][12 refs]. Int J Impot Res 2002;14Suppl-64.
Porst H. Transurethral alprostadil with MUSE (medicated urethral system for erection) vs intracavernous alprostadil—a comparative study in 103 patients with erectile dysfunction. Int J Impot Res. 1997;9(4):187-192. [pmid: 9442415].
Porst H. Phosphodiesterase type-5 inhibitors: A critical comparative analysis. Eau Update Series. 2004;2(2):56-63.
Porst H, Lungimayr G, utsch-osterreichische STEA. [Efficacy and tolerability of vardenafil within the time window of 6 hours after administration and beyond. Results of a clinical study carried out in 233 urological offices]. MMW Fortschr Med. 2005;147(Suppl 1):27-32. [pmid: 16739369].
Potempa AJ, Ulbrich E, Bernard I, et al. Efficacy of vardenafil in men with erectile dysfunction: a flexible-dose community practice study. Eur Urol. 2004;46(1):73-79. [pmid: 15183550].
Pradeep C, Car N, Metelko Z. Impotence in diabetic men. Diabetol Croat. 1996;25(2):61-68.
Price D. Sildenafil citrate (Viagra) efficacy in the treatment of erectile dysfunction in patients with common concomitant conditions. Sildenafil Study Group. Int J Clin Pract 1999;Supplement.102–103.
Price DE, Cooksey G, Jehu D, et al. The management of impotence in diabetic men by vacuum tumescence therapy. Diabet Med. 1991;8(10):964-967. [pmid: 1838050].
Prieto Castro RM, nglada Curado FJ, Regueiro Lopez JC, et al. Treatment with sildenafil citrate in renal transplant patients with erectile dysfunction. BJU Int. 2001;88(3):241-243. [pmid: 11488737].
Priyadarshi S. Oral terbutaline in the management of pharmacologically induced prolonged erection. Int J Impot Res. 2004;16(5):424-426. [pmid: 14999218].
Pryor J. Vardenafil: update on clinical experience. [Review][10 refs]. Int J Impot Res 2002;14Suppl-9.
Purvis K, Brekke I, Christiansen E. Determinants of satisfactory rigidity after intracavernosal injection with prostaglandin E1 in men with erectile failure. Int J Impot Res. 1996;8(1):9-16. [pmid: 8735188].
Radomski SB, Herschorn S, Rangaswamy S. Topical minoxidil in the treatment of male erectile dysfunction. Br J Urol. 1994;151(5):1225-1226.
Raffaele R, Vecchio I, Giammusso B, et al. Efficacy and safety of fixed-dose oral sildenafil in the treatment of sexual dysfunction in depressed patients with idiopathic Parkinson's disease. Eur Urol. 2002;41(4):382-386. [pmid: 12074807].
Raina R, Agarwal A, Allamaneni SS, et al. Sildenafil citrate and vacuum constriction device combination enhances sexual satisfaction in erectile dysfunction after radical prostatectomy. Urology. 2005;65(2):360-364. [pmid: 15708053].
Raina R, Agarwal A, Goyal KK, et al. Long-term potency after iodine-125 radiotherapy for prostate cancer and role of sildenafil citrate. Urology. 2003;62(6):1103-1108. [pmid: 14665364].
Raina R, Lakin MM, Agarwal A, et al. Long-term intracavernous therapy responders can potentially switch to sildenafil citrate after radical prostatectomy. Urology. 2004;63(3):532-537. [pmid: 15028452].
Raina R, Lakin MM, Agarwal A, et al. Efficacy and factors associated with successful outcome of sildenafil citrate use for erectile dysfunction after radical prostatectomy. Urology. 2004;63(5):960-966. [pmid: 15134989].
Raina R, Lakin MM, Agarwal A, et al. Long-term effect of sildenafil citrate on erectile dysfunction after radical prostatectomy: 3-year follow-up. Urology. 2003;62(1):110-115. [pmid: 12837433].
Raina R, Lakin MM, Thukral M, et al. Long-term efficacy and compliance of intracorporeal (IC) injection for erectile dysfunction following radical prostatectomy: SHIM (IIEF-5) analysis. Int J Impot Res. 2003;15(5):318-322. [pmid: 14562131].
Rajpurkar A, Dhabuwala CB. Comparison of satisfaction rates and erectile function in patients treated with sildenafil, intracavernous prostaglandin E1 and penile implant surgery for erectile dysfunction in urology practice. Br J Urol. 2003;170(1):159-163.
Rakic Z, Starcevic V, Starcevic VP, et al. Testosterone treatment in men with erectile disorder and low levels of total testosterone in serum. Arch Sex Behav. 1997;26(5):495-504. [pmid: 9343635].
Ralph DJ, Sleep DJ, Perdok RJ, et al. Adverse events and patient tolerability of apomorphine SL 2 and 3 mg: A cross-study analysis of phase II and III studies. European Urology Supplements. 2002;1(3):21-27.
Ramasubbu Rajamannar. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Rashid A. The efficacy and safety of PDE5 inhibitors. [Review] [30 refs]. Clin Cornerstone. 2005;7(1):47-56. [pmid: 16156423].
Reiter WJ, Schatzl G, Mark I, et al. Dehydroepiandrosterone in the treatment of erectile dysfunction in patients with different organic etiologies. Urol Res. 2001;29(4):278-281. [pmid: 11585284].
Reznik I, Zemishlany Z, Kotler M, et al. Sildenafil citrate for the sexual dysfunction in antidepressant-treated male patients with posttraumatic stress disorder. A preliminary pilot open-label study. Psychotherapy & Psychosomatics. 2002;71(3):173-176. [pmid: 12021561].
Richardson JD. Intracorporeal injections for the treatment of impotence. Med J Aust. 1991;155(10):688. [pmid: 1943899].
Richter S, Vardi Y, Ringel A, et al. Intracavernous injections: still the gold standard for treatment of erectile dysfunction in elderly men. Int J Impot Res. 2001;13(3):172-175. [pmid: 11525316].
Rizvi K, Hampson JP, Harvey JN. Do lipid-lowering drugs cause erectile dysfunction? A systematic review.[see comment]. [Review] [35 refs]. Fam Pract. 2002;19(1):95-98. [pmid: 11818357].
Roach M, Winter K, Michalski JM, et al. Penile bulb dose and impotence after three-dimensional conformal radiotherapy for prostate cancer on RTOG 9406: findings from a prospective, multi-institutional, phase I/II dose-escalation study. Int J Radiat Oncol Biol Phys. 2004;60(5):1351-1356. [pmid: 15590164].
Robinson PK. An observational study of prostaglandin E-1: comparing trial and maintenance dose. Urol Nurs. 1994;14(3):76-78. [pmid: 7732420].
Rodilla F, Fuentes MD, Chuan P, et al. Penile self-injection for impotence in patients after radical cystectomy. Journal of Clinical Pharmacy & Therapeutics. 1994;19(6):359-360. [pmid: 7876367].
Rodrigues M, Granegger S, O'Grady J, et al. Accumulation of platelets as a key mechanism of human erection. A scintigraphic study in patients with erectile dysfunction receiving intracavernous injection of PGE1, papaverine/phentolamine. Advances in Experimental Medicine & Biology. 1997;43:379-82.
Rodrigues M, O'Grady J, Stackl W, et al. Accumulation of platelets as a key mechanism of human erection. Thromb Res. 1998;91(2):53-56. [pmid: 9722020].
Rodriguez Vela L, Lledo Garcia E, Rajmil O, et al. [Tadalafil vs sildenafil patient preference in Spanish men with erectile dysfunction: results from an International Multicentric Study]. Actas Urol Esp. 2006;30(1):67-79. [pmid: 16703733].
Rosas SE, Wasserstein A, Kobrin S, et al. Preliminary observations of sildenafil treatment for erectile dysfunction in dialysis patients. Am J Kidney Dis. 2001;37(1):134-137. [pmid: 11136178].
Rosas-Vargas H, Coral-Vazquez RM, Tapia R, et al. Glu298Asp endothelial nitric oxide synthase polymorphism is a risk factor for erectile dysfunction in the Mexican Mestizo population. J Androl. 2004;25(5):728-732. [pmid: 15292102].
Rosen RC, Shabsigh R, Kuritzky L, et al. The efficacy of tadalafil in improving sexual satisfaction and overall satisfaction in men with mild, moderate, and severe erectile dysfunction: A retrospective pooled analysis of data from randomized, placebo-controlled clinical trials. Current Medical Research & Opinion. 2005;21(11):1701-1709. [pmid: 16307689].
Rosen R, Janssen E, Wiegel M, et al. Psychological and interpersonal correlates in men with erectile dysfunction and their partners: a pilot study of treatment outcome with sildenafil. J Sex Marital Ther. 2006;32(3):215-234. [pmid: 16809250].
Rosenstock HA, Axelrad SD. Erectile dysfunction: on the efficacy of a phosphodiesterase inhibitor with concurrent sex therapy. Asian J Androl. 1999;1(4):207-210. [pmid: 11225896].
Rowland DL, Boedhoe HSM, Dohle G, et al. Intracavernosal self-injection therapy in men with erectile dysfunction: Satisfaction and attrition in 119 patients. Int J Impot Res. 1999;11(3):145-151. [pmid: 10404283].
Rowland DL, Myers L, Culver A, et al. Bupropion and sexual function: a placebo-controlled prospective study on diabetic men with erectile dysfunction. J Clin Psychopharmacol. 1997;17(5):350-357. [pmid: 9315985].
Rubio-Aurioles E, Porst H, Eardley I, et al. Comparing vardenafil and sildenafil in the treatment of men with erectile dysfunction and risk factors for cardiovascular disease: a randomized, double-blind, pooled crossover study. Br J Sex Med. 2006;3(6):1037-1049.
Rudkin L, Taylor M J, Hawton K. Strategies for managing sexual dysfunction induced by antidepressant medication. [Review][61 refs]. Cochrane Database Syst Rev 2004;(4):CD003382
Ruof J, Graf-Morgenstern M, Mnller MJ. Quality of life in patients with erection difficulties: Evaluation of a German version of the "Quality of life measure for men with erection difficulties" (QoL-Med). Aktuel Urol. 2001;32(1):21-26.
Saad F, Grahl AS, Aversa A, et al. Effects of testosterone on erectile function: implications for the therapy of erectile dysfunction. BJU Int. 2007;99(5):988-992. [pmid: 17309554].
Saad F, Hoesl CE, Oettel M, et al. Dehydroepiandrosterone treatment in the aging male - What should the urologist know?. Eur Urol. 2005;48(5):724-733. [pmid: 16137821].
Sadeghi-Nejad H, Lim H, Long K, et al. Assessment of the efficacy of Viagra (sildenafil citrate) using the Erectile Dysfunction Inventory of Treatment Satisfaction (EDITS). Urol Int. 2003;71(1):100-102. [pmid: 12845271].
Sadovsky R, Althof S. Men's sexual issues. Clinics in Family Practice. 2004;6(4 SPEC.ISS.):863-915.
Sahu MA, Ayyaz M, Chaudhry Z. Intracavernous injections of papaverine and phentolamine for treatment of impotence. J Coll Physicians Surg Pak. 1997;7(3):102-104.
Saie DJ, Sills ES. Hyperprolactinemia presenting with encephalomalacia-associated seizure disorder and infertility: A novel application for bromocriptine therapy in reproductive endocrinology. Neuroendocrinol Lett. 2005;26(5):533-537. [pmid: 16264405].
Salama N. Nocturnal electrobioimpedance volumetric assessment in diabetic men with erectile dysfunction before and after tadalafil intake. Int J Impot Res. 2004;16(5):441-447. [pmid: 15057255].
Salonia A, Rigatti P, Montorsi F. Sildenafil in erectile dysfunction: a critical review. Curr Med Res Opin. 2003;19(4):241-262. [pmid: 12841917].
Salonia Andrea, Briganti Alberto, Montorsi Piero, et al. Safety and tolerability of oral erectile dysfunction treatments in the elderly. [References]. Drugs and Aging. 2005;22(4):323-338. [pmid: 15839721].
Sato Y, Horita H, Adachi H, et al. Effect of oral administration of prostaglandin E1 on erectile dysfunction. Br J Urol. 1997;80(5):772-775. [pmid: 9393301].
Savoca G, Silvestre G, Belgrano E. Intracavernosal injection therapy and surgical therapy in diabetic patients with erectile dysfunction. [Review] [26 refs]. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):53-57.
Schanz S, Hauswirth U, Ulmer A, et al. Prostaglandin E(1) ethyl ester, a new agent for topical penile therapy. Int J Impot Res. 2002;14(4):317-318. [pmid: 12152124].
Schimmer AD, Ali V, Stewart AK, et al. Male sexual function after autologous blood or marrow transplantation. Biology of Blood & Marrow Transplantation. 2001;7(5):279-283. [pmid: 11400950].
Schmid DM, Schurch B, Hauri D. Sildenafil in the treatment of sexual dysfunction in spinal cord-injured male patients. Eur Urol. 2000;38(2):184-193. [pmid: 10895011].
Schouman M, Lacroix P, Amer M. Suppression of prostaglandin E1-induced pain by dilution of the drug with lidocaine before intracavernous injection. Br J Urol. 1992;148(4):1266.
Schroder FH, Whelan P, De Reijke TM, et al. Metastatic prostate cancer treated by flutamide versus cyproterone acetate. Final analysis of the "European Organization for Research and Treatment of Cancer" (EORTC) Protocol 30892. Eur Urol. 2004;45(4):457-464. [pmid: 15041109].
Schulman CC, Shen W, Stothard DR, et al. Integrated analysis examining first-dose success, success by dose, and maintenance of success among men taking tadalafil for erectile dysfunction. Urology. 2004;64(4):783-788. [pmid: 15491720].
Schultheiss D, Stief CG. Physiology and pathophysiology of erection: Consequences for present medical therapy of erectile dysfunction. Andrologia. 1999;31(SUPPL. 1):59-64. [pmid: 10643521].
Schultheiss D, Hiltl DM, Meschi MR, et al. Pilot study of the transdermal application of testosterone gel to the penile skin for the treatment of hypogonadotropic men with erectile dysfunction. World J Urol. 2000;18(6):431-435. [pmid: 11204264].
Seftel AD. From aspiration to achievement: Assessment and noninvasive treatment of erectile dysfunction in aging men. J Am Geriatr Soc. 2005;53(1):119-130. [pmid: 15667388].
Segraves RT, Lee J, Stevenson R, et al. Tadalafil for treatment of erectile dysfunction in men on antidepressants. J Clin Psychopharmacol. 2007;27(1):62-66. [pmid: 17224715].
Seidman SN, Pesce VC, Roose SP. High-dose sildenafil citrate for selective serotonin reuptake inhibitor-associated ejaculatory delay: open clinical trial. Hillside J Clin Psychiatry. 2003;64(6):721-725.
Setter SM, Iltz JL, Fincham JE, et al. Phosphodiesterase 5 inhibitors for erectile dysfunction. [Review] [75 refs]. Ann Pharmacother. 2005;39(78):1286-1295. [pmid: 15941818].
Sexton WJ, Benedict JF, Jarow JP. Comparison of long-term outcomes of penile prostheses and intracavernosal injection therapy.[see comment]. Br J Urol. 1998;159(3):811-815.
Shabbir M, Mikhailidis DM, Morgan RJ. Erectile dysfunction: an underdiagnosed condition associated with multiple risk factors.[comment]. Current Medical Research & Opinion. 2004;20(5):603-606. [pmid: 15140326].
Shabsigh R. Testosterone therapy in erectile dysfunction and hypogonadism. Br J Sex Med. 2005;2(6):785-792.
Shabsigh R. Hypogonadism and erectile dysfunction: The role for testosterone therapy. Int J Impot Res. 2003;15(SUPPL. 4):S9-S13. [pmid: 12934045].
Shabsigh R, Burnett AL, Eardley I, et al. Time from dosing to sexual intercourse attempts in men taking tadalafil in clinical trials. BJU Int. 2005;96(6):857-863. [pmid: 16153217].
Shabsigh R, Katz M, Yan G, et al. Cardiovascular issues in hypogonadism and testosterone therapy. [Review] [44 refs]. Am J Cardiol. 2005;96(12B):67M-72M. [pmid: 15979436].
Shabsigh R, Padma-Nathan H, Gittleman M, et al. Intracavernous alprostadil alfadex (EDEX/VIRIDAL) is effective and safe in patients with erectile dysfunction after failing sildenafil (Viagra). Urology. 2000;55(4):477-480. [pmid: 10736486].
Shamloul R. Management of honeymoon impotence. Br J Sex Med. 2006;3(2):361-366.
Shamloul R, Atteya A, Elnashaar A, et al. Intracavernous sodium nitroprusside (SNP) versus papaverine/phentolamine in erectile dysfunction: A comparative study of short- term efficacy and side- effects. Br J Sex Med. 2005;2(1):117-120.
Shamloul Rany, Kamel Ihab, et al. Early Treatment of Cavernositis Resulted in Erectile Function Preservation. [References]. Br J Sex Med. 2006;3(2):320-322.
Sharlip ID. Editorial comment. International Braz J Urol. 2005;31(4):354-355.
Sharlip ID. Can self-injection therapy cure impotence?. [Review] [7 refs]. Advances in Experimental Medicine & Biology. 1997;43:383-86.
Sharma RK, Prasad N, Kapoor R, et al. Treatment of erectile dysfunction with sidenafil citrate in renal transplant recipient: a cross over placebo controlled trial [abstract]. Indian Journal of Nephrology. 2002;12(4):23-238.
Shemtov OM, Radomski SB, Crook J. Success of sildenafil for erectile dysfunction in men treated with brachytherapy or external beam radiation for prostate cancer. Can J Urol. 2004;11(6):2450-2455. [pmid: 15636671].
Shenfeld OZ, Gofrit ON, Gdor Y, et al. The role of sildenafil in the treatment of erectile dysfunction in patients with pelvic fracture urethral disruption. Br J Urol. 2004;172(6 I):2350-2352.
Sheu JY, Chen KK, Lin AT, et al. Long-term efficacy and safety of sildenafil for patients with erectile dysfunction. Journal of the Chinese Medical Association: JCMA. 2003;66(8):480-486. [pmid: 14604312].
Shigemura K, Arakawa S, Kamidono S, et al. Effect of sildenafil on arterial stiffness, as assessed by pulse wave velocity, in patients with erectile dysfunction. Int J Urol. 2006;13(7):956-959. [pmid: 16882062].
Shimon I, Lubina A, Gorfine M, et al. Feedback inhibition of gonadotropins by testosterone in men with hypogonadotropic hypogonadism: comparison to the intact pituitary-testicular axis in primary hypogonadism. J Androl. 2006;27(3):358-364. [pmid: 16474013].
Shokeir AA, Alserafi MA, Mutabagani H. Intracavernosal versus intraurethral alprostadil: a prospective randomized study. BJU Int. 1999;83(7):812-815. [pmid: 10368203].
Siegel RL, Dubin NH, Andrade JR. Sildenafil citrate and sperm function [3] (multiple letters). American Journal of Obstetrics & Gynecology. 2001;184(4):777-778. [pmid: 11262489].
Sighinolfi MC, de Stefani S, Mofferdin A, et al. Intracavernous prostaglandin E1 infusion in diabetes with associated ischemic necrosis of the glans penis. Br J Urol. 2004;171(6 I):2380.
Silvestri A, Galetta P, Cerquetani E, et al. Report of erectile dysfunction after therapy with beta-blockers is related to patient knowledge of side effects and is reversed by placebo.[see comment]. Eur Heart J. 2003;24(21):1928-1932. [pmid: 14585251].
Singh AN, Scurlock H, Catalan J. Paroxetine induced erectile dysfunction successfully treated with yohimbine in patients suffering from HIV infection. Journal of Serotonin Research. 1995;1(4):283-285.
Slob AK, Verhulst ACM, Gijs L, et al. Intracavernous injection during diagnostic screening for erectile dysfunction: Five-year experience with over 600 patients. [References]. Br J Sex Med. 2002;28(1):61-70.
Smith KM, Romanelli F. Recreational use and misuse of phosphodiesterase 5 inhibitors. [Review] [56 refs]. Journal of the American Pharmacists Association: JAPhA. 2005;45(1):63-72. [pmid: 15730119].
Soh J, Naya Y, Ushijima S, et al. Efficacy of sildenafil for Japanese patients with audio-visual sexual stimulation (AVSS) test by the RigiScan Plus. Arch Androl. 2006;52(3):163-168. [pmid: 16574596].
Soler JM, Previnaire JG, Denys P, et al. Phosphodiesterase inhibitors in the treatment of erectile dysfunction in spinal cord-injured men. Proc Annu Clin Spinal Cord Inj Conf. 2007;45(2):169-173.
Sommer F, Engelmann U. Vardenafil: Bayer Yakuhin. Curr Opin Investig Drugs. 2002;3(4):607-613.
Sonksen J, Biering-Sorensen F. Transcutaneous nitroglycerin in the treatment of erectile dysfunction in spinal cord injured. Paraplegia. 1992;30(8):554-557. [pmid: 1522996].
Sparwasser C, Treiber U, Bahren W, et al. Postoperative erectile dysfunction; evaluation and treatment with intracavernous vasoactive injections. Progress in Clinical & Biological Research. 1991;370:349-354. [pmid: 1924468].
Speckens AE, Kattemolle MR, Hengeveld MW, et al. A prospective long-term follow-up study of patients evaluated for erectile dysfunction: outcome and associated factors. Int J Impot Res. 1995;7(2):101-110. [pmid: 7496438].
Speel TGW, Bleumer I, Diemont WL, et al. The value of sildenafil as mode of stimulation in pharmaco-penile duplex ultrasonography. Int J Impot Res. 2001;13(4):189-191. [pmid: 11494073].
Sperling H, Eisenhardt A, Virchow S, et al. Sildenafil response is influenced by the G protein beta 3 subunit GNB3 C825T polymorphism: a pilot study. Br J Urol. 2003;169(3):1048-1051.
Stanislavov R, Nikolova V. Treatment of erectile dysfunction with pycnogenol and L-arginine. J Sex Marital Ther. 2003;29(3):207-213. [pmid: 12851125].
Steers W, Guay AT, Leriche A, et al. Assessment of the efficacy and safety of Viagra (sildenafil citrate) in men with erectile dysfunction during long-term treatment. Int J Impot Res. 2001;13(5):261-267. [pmid: 11890512].
Steidle CP, McCullough AR, Kaminetsky JC, et al. Early sildenafil dose optimization and personalized instruction improves the frequency, flexibility, and success of sexual intercourse in men with erectile dysfunction. Int J Impot Res. 2007;19(2):154-160. [pmid: 16858367].
Stephenson RA, Mori M, Hsieh YC, et al. Treatment of erectile dysfunction following therapy for clinically localized prostate cancer: patient reported use and outcomes from the Surveillance, Epidemiology, and End Results Prostate Cancer Outcomes Study. Br J Urol. 2005;174(2):646-650.
Stief CG, Holmquist F, Djamilian M, et al. Preliminary results with the nitric oxide donor linsidomine chlorhydrate in the treatment of human erectile dysfunction. Br J Urol. 1992;148(5):1437-1440.
Stief CG, Uckert S, Jonas U. Strategies in the oral pharmacotherapy of male erectile dysfunction viewed from bench and bedside (Part II). The Journal of Mens Health & Gender. 2005;2(3):325-332.
Stief CG, Wetterauer U, Schaebsdau FH, et al. Calcitonin-gene-related peptide: a possible role in human penile erection and its therapeutic application in impotent patients. Br J Urol. 1991;146(4):1010-1014.
Stief C, Padley RJ, Perdok RJ, et al. Cross-study review of the clinical efficacy of apomorphine SL 2 and 3 mg: Pooled data from three placebo-controlled, fixed-dose crossover studies. European Urology Supplements. 2002;1(3):12-20.
Strahilevitz J, Rahav G, Schroers HJ, et al. An outbreak of Phialemonium infective endocarditis linked to intracavernous penile injections for the treatment of impotence. Clin Infect Dis. 2005;40(6):781-786. [pmid: 15736008].
Stroberg P, Murphy A, Costigan T. Switching patients with erectile dysfunction from sildenafil citrate to tadalafil: results of a European multicenter, open-label study of patient preference. Clin Ther. 2003;25(11):2724-2737. [pmid: 14693300].
Stuckey BGA. Tadalafil phase 3 experience. European Urology Supplements. 2002;1(8):25-30.
Swartz DA, Todd MW. Intracavernous papaverine and glaucoma.[see comment]. JAMA. 1990;264(5):570. [pmid: 2366292].
Tam PY, Keller T, Poppiti R, et al. Hemodynamic effects of transurethral alprostadil measured by color duplex ultrasonography in men with erectile dysfunction. Br J Urol. 1998;160(4):1321-1324.
Tam SW, Worcel M, Wyllie M. Yohimbine: a clinical review. [Review] [152 refs]. Pharmacol Ther. 2001;91(3):215-243. [pmid: 11744068].
Tanaka T. Papaverine hydrochloride in peripheral blood and the degree of penile erection. Br J Urol. 1990;143(6):1135-1137.
Tariq SH, Haleem U, Omran ML, et al. Erectile dysfunction: Etiology and treatment in young and old patients. Clin Geriatr Med. 2003;19(3):539-551. [pmid: 14567006].
Tas A, Ersoy A, Ersoy C, et al. Efficacy of sildenafil in male dialysis patients with erectile dysfunction unresponsive to erythropoietin and/or testosterone treatments. Int J Impot Res. 2006;18(1):61-68. [pmid: 16177828].
Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005;88(3):241-254. [pmid: 16162361].
Tekdogan U, Tuncel A, Tuglu D, et al. Effect of sildenafil citrate treatment on serum dehydroepiandrosterone sulfate levels in patients with erectile dysfunction. Urology. 2006;68(3):626-630. [pmid: 16979704].
Telias Isaac Darwin, Kadmon-Telias Ana, et al. Four cases of erectile dysfunction in substance abusers treated with sildenafil. [References]. J Addict Dis. 2002;97(11):1473-1474.
Teloken C, Rhoden EL, Sogari P, et al. Therapeutic effects of high dose yohimbine hydrochloride on organic erectile dysfunction. Br J Urol. 1998;159(1):122-124.
Terradas C, Levalle O, Nagelberg A, et al. Sildenafil improves nocturnal penile erections in organic impotence. Int J Impot Res. 2001;13(2):125-129. [pmid: 11426352].
Tomlinson John M, Wright David, E-Mail Address et al. Impact of erectile dysfunction and its subsequent treatment with sildenafil: Qualitative study. [References]. BMJ: British Medical Journal 2004;328(7447):No
Tomsak R. PDE5 inhibitors and permanent visual loss. Int J Impot Res. 2005;17(6):547-549. [pmid: 16193072].
Tosti A, Pazzaglia M, Soli M, et al. Evaluation of sexual function with an international index of erectile function in subjects taking finasteride for androgenetic alopecia.[see comment]. Arch Dermatol. 2004;140(7):857-858. [pmid: 15262698].
Trinchieri A, Nicola M, Masini F, et al. Prospective comprehensive assessment of sexual function after retropubic non nerve sparing radical prostatectomy for localized prostate cancer. Arch Ital Urol Androl. 2005;77(4):219-223. [pmid: 16444937].
Truss MC, Becker AJ, Thon WF, et al. Intracavernous calcitonin gene-related peptide plus prostaglandin E1: possible alternative to penile implants in selected patients. Eur Urol. 1994;26(1):40-45. [pmid: 7925528].
Tsai YS, Lin JS, Lin YM. Safety and efficacy of alprostadil sterile powder (S. Po., CAVERJECT) in diabetic patients with erectile dysfunction. Eur Urol. 2000;38(2):177-183. [pmid: 10895010].
Tsujimura A, Yamanaka M, Takahashi T, et al. The clinical studies of sildenafil for the ageing male. Int J Androl. 2002;25(1):28-33. [pmid: 11869374].
Turk S, Karalezli G, Tonbul HZ, et al. Erectile dysfunction and the effects of sildenafil treatment in patients on haemodialysis and continuous ambulatory peritoneal dialysis. Nephrol.Dial.Transplant. 2001;16(9):1818-1822. [pmid: 11522864].
Turner LA, Althof SE. The clinical effectiveness of self-injection and external vacuum devices in the treatment of erectile dysfunction: a six-month comparison. Psychiatr Med. 1992;10(2):283-293. [pmid: 1377397].
Turner LA, Althof SE, Levine SB, et al. Twelve-month comparison of two treatments for erectile dysfunction: self-injection versus external vacuum devices. Urology. 1992;39(2):139-144. [pmid: 1736506].
Urciuoli R, Cantisani T A, CarliniI M et al. Prostaglandin E1 for treatment of erectile dysfunction. Cochrane Database Syst Rev 2004;(2):CD001784
Valicenti RK, Choi E, Chen C, et al. Sildenafil citrate effectively reverses sexual dysfunction induced by three-dimensional conformal radiation therapy. Urology. 2001;57(4):769-773. [pmid: 11306401].
Valiquette L, Montorsi F, Hellstrom WJ, et al. Penetration and maintenance of erection with vardenafil: a time-from-dosing analysis. Can J Urol. 2005;12(3):2687-2698. [pmid: 16011816].
van Basten JP, Van Driel MF, Jonker-Pool G, et al. Sexual functioning in testosterone-supplemented patients treated for bilateral testicular cancer. Br J Urol. 1997;79(3):461-467. [pmid: 9117232].
van Moorselaar RJ, Hartung R, Emberton M, et al. Alfuzosin 10 mg once daily improves sexual function in men with lower urinary tract symptoms and concomitant sexual dysfunction. BJU Int. 2005;95(4):603-608. [pmid: 15705088].
Van Ahlen H, Peskar BA, Sticht G, et al. Pharmacokinetics of vasoactive substances administered into the human corpus cavernosum. Br J Urol. 1994;151(5):1227-1230.
Van Dijk M, Skrekas T, De La, et al. The association between lower urinary tract symptoms and sexual dysfunction: Fact or fiction?. Curr Opin Urol. 2005;15(1):39-44. [pmid: 15586029].
Vardi M, Nini A. Phosphodiesterase inhibitors for erectile dysfunction in patients with diabetes mellitus. [Review][49 refs]. Cochrane Database Syst Rev 2007;(1):CD002187
Vardi Y, Sprecher E, Gruenwald I. Logistic regression and survival analysis of 450 impotent patients treated with injection therapy: long-term dropout parameters. Br J Urol. 2000;163(2):467-470.
Vickers MA, De Nobrega AM, Dluhy RG. Diagnosis and treatment of psychogenic erectile dysfunction in a urological setting: Outcomes of 18 consecutive patients. Br J Urol. 1993;149(5 SUPPL.):1258-1261.
Virag R. Indications and early results of sildenafil (Viagra) in erectile dysfunction. Urology. 1999;54(6):1073-1077. [pmid: 10604711].
Virag R. Intracavernous injection of papaverine for erectile failure. 1982. Br J Urol. 2002;167(2 Pt 2):1196.
Virag R, Floresco J, Richard C. Impairment of shear-stress-mediated vasodilation of cavernous arteries in erectile dysfunction. Int J Impot Res. 2004;16(1):39-42. [pmid: 14963469].
Vitezic D. A risk-benefit assessment of sildenafil in the treatment of erectile dysfunction. [Review] [72 refs]. Drug Saf. 2001;24(4):255-265. [pmid: 11330655].
von Heyden B, Donatucci CF, Kaula N, et al. Intracavernous pharmacotherapy for impotence: selection of appropriate agent and dose. [Review] [23 refs]. Br J Urol. 1993;149(5 Pt 2):1288-1290.
Wagner G, Montorsi F, Auerbach S, et al. Sildenafil citrate (VIAGRA) improves erectile function in elderly patients with erectile dysfunction: a subgroup analysis. J Gerontol A Biol.Sci Med Sci. 2001;56(2):M113-M119. [pmid: 11213274].
Wagrell L, Schelin S, Nordling J, et al. Three-year follow-up of feedback microwave thermotherapy versus TURP for clinical BPH: a prospective randomized multicenter study. Urology. 2004;64(4):698-702. [pmid: 15491704].
Wang CJ, Wu CC, Huang CH, et al. A comparative study with intracavernous injection of prostaglandin E1 versus papaverine for the diagnostic assessment of erectile impotence. Gaoxiong Yi Xue Ke Xue Za Zhi. 1992;8(11):585-590. [pmid: 1296038].
Wang ZL, Shao SX, Li B, et al. Sildenafil versus prostaglandin E1 in the management of erectile dysfunction. Journal of Clinical Urology. 2002;17(7):347-349.
Webb DJ, Freestone S, Allen MJ, et al. Sildenafil citrate and blood-pressure-lowering drugs: results of drug interaction studies with an organic nitrate and a calcium antagonist. Am J Cardiol. 1999;83(5A):21C-28C. [pmid: 10073779].
Weber DC, Bieri S, Kurtz JM, et al. Prospective pilot study of sildenafil for treatment of postradiotherapy erectile dysfunction in patients with prostate cancer. Am J Clin Oncol. 1999;17(11):3444-3449.
Weidner W, Schroeder-Printzen I, Fischer C, et al. Experience in the treatment of erectile dysfunction using the intracavernosal self-injection of papaverine: Results of a prospective study after a median follow-up of 42 months involving 135 patients and 10766 injections. World J Urol. 1992;10(3):179-182.
Weiss JN, Badlani GH, Ravalli R, et al. Reasons for high drop-out rate with self-injection therapy for impotence. Int J Impot Res. 1994;6(3):171-174. [pmid: 7735362].
Weiss JN, Ravalli R, Badlani GH. Intracavernous pharmacotherapy in psychogenic impotence. Urology. 1991;37(5):441-443. [pmid: 1708925].
Wen HS, Hsieh CH, Hsu GL, et al. The synergism of penile venous surgery and oral sildenafil in treating patients with erectile dysfunction.[see comment]. Int J Androl. 2005;28(5):297-303. [pmid: 16128990].
Werneke U, Crowe M. Review of patients with erectile dysfunction attending the Maudsley psychosexual clinic in 1999: The impact of sildenafil. Sexual & Relationship Therapy. 2002;17(2):171-185.
Werthman P, Rajfer J. MUSE therapy: preliminary clinical observations. Urology. 1997;50(5):809-811. [pmid: 9372900].
Wespes E, Rammal A, Garbar C. Sildenafil non-responders: haemodynamic and morphometric studies. Eur Urol. 2005;48(1):136-139. [pmid: 15967263].
Williams G. Male erectile dysfunction. Prescribers' Journal. 2000;40(1):49-58.
Williams G, Abbou CC, Amar ET, et al. The effect of transurethral alprostadil on the quality of life of men with erectile dysfunction, and their partners. MUSE Study Group. Br J Urol. 1998;82(6):847-854. [pmid: 9883223].
Williams T, Honeywell M, Branch E et al. Tadalafil in the treatment of erectile dysfunction. P & T 2004;29(5):
Willke RJ, Glick HA, McCarron TJ, et al. Quality of life effects of alprostadil therapy for erectile dysfunction. Br J Urol. 1997;157(6):2124-2128.
Wise Thomas N. Psychosocial side effects of sildenafil therapy for erectile dysfunction. J Sex Marital Ther. 1999;25(2):145-150. [pmid: 10327384].
Wolfson B, Pickett S, Scott NE, et al. Intraurethral prostaglandin E-2 cream: a possible alternative treatment for erectile dysfunction. Urology. 1993;42(1):73-75. [pmid: 8328127].
Wood P L. Slow, tedious but essential: The need for incremental R&D. Current Drug Discovery 2004;(pp 31–35):-35.
Wu CC, Xue ZY, Apichat K, et al. The use of alprostadil sterile powder in a home self-injection study of Asian men with erectile dysfunction. Clin Ther. 1996;18(2):256-264. [pmid: 8733986].
Wylie Kevan R, Hallam-Jones Ruth A, Steward David, et al. The combination of penoscrotal rings and PDE5i's in the treatment of erectile dysfunction - the Sheffield PDE5i and Ring Duo Technique. Two case reports. [References]. Sexual and Relationship Therapy. 2006;21(2):209-215.
Yaman O, Akand M, Gursoy A, et al. The effect of diabetes mellitus treatment and good glycemic control on the erectile function in men with diabetes mellitus-induced erectile dysfunction: a pilot study. Br J Sex Med. 2006;3(2):344-348.
Yaman O, Tokatli Z, Akand M, et al. Characteristics of sildenafil erections in healthy young men. Asian J Androl. 2005;7(4):395-398. [pmid: 16281087].
Yassin AA, Saad F. Improvement of sexual function in men with late-onset hypogonadism treated with testosterone only. Br J Sex Med. 2007;4(2):497-501.
Yassin AA, Saad F. Dramatic improvement of penile venous leakage upon testosterone administration. A case report and review of literature. Andrologia. 2006;38(1):34-37. [pmid: 16420241].
Yassin AA, Saad F, Traish A. Testosterone undecanoate restores erectile function in a subset of patients with venous leakage: a series of case reports. Br J Sex Med. 2006;3(4):727-735.
Yenicerioglu Y, Kefi A, Aslan G, et al. Efficacy and safety of sildenafil for treating erectile dysfunction in patients on dialysis. BJU Int. 2002;90(4):442-445. [pmid: 12175405].
Zaher TF. Papaverine plus prostaglandin E1 versus prostaglandin E1 alone for intracorporeal injection therapy. Int Urol Nephrol. 1998;30(2):193-196. [pmid: 9607891].
Zargooshi J. Unconsummated marriage: clarification of aetiology; treatment with intracorporeal injection. BJU Int. 2000;86(1):75-79. [pmid: 10886087].
Zasler ND. Therapeutic approaches to sexual impotence. Hospital Practice (Office Edition). 1988;23(7):197-200.
Zelefsky MJ, McKee AB, Lee H, et al. Efficacy of oral sildenafil in patients with erectile dysfunction after radiotherapy for carcinoma of the prostate. Urology. 1999;53(4):775-778. [pmid: 10197855].
Zesiewicz TA, Helal M, Hauser RA. Sildenafil citrate (Viagra) for the treatment of erectile dysfunction in men with Parkinson's disease. Mov Disord. 2000;15(2):305-308. [pmid: 10752581].
Zhang Y, Guan DL, Ou TW, et al. Sildenafil citrate treatment for erectile dysfunction after kidney transplantation. Transplant Proc. 2005;37(5):2100-2103. [pmid: 15964350].
Ziegler D. Management of erectile dysfunction in diabetic patients. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):58-65.
Zippe CD, Kedia AW, Kedia K, et al. Treatment of erectile dysfunction after radical prostatectomy with sildenafil citrate (Viagra). Urology. 1998;52(6):963-966. [pmid: 9836537].
Zippe CD, Kedia S, Kedia AW, et al. Sildenafil citrate (Viagra) after radical retropubic prostatectomy: pro. Urology. 1999;54(4):583-586. [pmid: 10510910].
Zlotta AR, Teillac P, Raynaud JP, et al. Evaluation of male sexual function in patients with Lower Urinary Tract Symptoms (LUTS) associated with Benign Prostatic Hyperplasia (BPH) treated with a phytotherapeutic agent (Permixon), Tamsulosin or Finasteride. Eur Urol. 2005;48(2):269-276. [pmid: 15939527].
Zorgniotti A. ‘“On demand” oral drug for erection in impotent men’. Br J Urol 1992;147308
Zorgniotti AW. Experience with buccal phentolamine mesylate for impotence. Int J Impot Res. 1994;6(1):37-41. [pmid: 7517275].
Zusman RM, Morales A, Glasser DB, et al. Overall cardiovascular profile of sildenafil citrate. [Review] [33 refs]. Am J Cardiol. 1999;83(5A):35C-44C.

## Not applicable

Annual update 2004/2005 - Treatment of genitourinary disorders. Drugs of the Future 2005;30(9):931–934.
Abrams J. Time course of the interaction between tadalafil and nitrates.[comment]. J Am Coll Cardiol. 2004;43(11):2150-2151. [pmid: 15172433].
Adaikan PG, Chong YS, Chew SSL, et al. Male sexual dysfunction. Curr Obstet Gynaecol. 2000;10(1):23-28.
Ahl J, Kinon B J, Liu-Seifert H. Sexual dysfunction associated with neuroleptic-induced hyperprolactinemia improves with reduction in prolactin levels. Ann N Y Acad Sci 2004;1032(pp 289–290):-290.
Ahuja SK, Krane NK, Hellstrom WJ. Penile prostheses in the management of impotence in patients with end-stage renal disease. J La State Med Soc. 1998;150(1):32-34. [pmid: 9448384].
Akbari F, Alavi M, Esteghamati A, et al. Effect of renal transplantation on sperm quality and sex hormone levels. BJU Int. 2003;92(3):281-283. [pmid: 12887484].
Akkus E, Kadioglu A, Esen A, et al. Prevalence and correlates of erectile dysfunction in Turkey: a population-based study. Eur Urol. 2002;41(3):298-304. [pmid: 12180232].
Alexandre B, Lemaire A, Desvaux P, et al. Intracavernous injections of prostaglandin E1 for erectile dysfunction: patient satisfaction and quality of sex life on long-term treatment. Br J Sex Med. 2007;4(2):426-431.
Alfonso A, Rieniets KI, Vigersky RA. Incidence and clinical significance of elevated macroprolactin levels in patients with hyperprolactinemia. Endocr Pract. 2006;12(3):275-280. [pmid: 16772199].
Alivizatos G, Skolarikos A, Laguna P. Recent data upon impotence, incontinence and quality of life issues concerning radical prostatectomy. [Review] [74 refs]. Arch Esp Urol. 2003;56(3):321-330. [pmid: 12768997].
Althof SE. Quality of life and erectile dysfunction. Urology. 2002;59(6):803-810. [pmid: 12031357].
Althof SE, Corty EW, Levine SB, et al. EDITS: development of questionnaires for evaluating satisfaction with treatments for erectile dysfunction. Urology. 1999;53(4):793-799. [pmid: 10197859].
Althof Stanley E, Turner Louisa A. Self-injection therapy and external vacuum devices in the treatment of erectile dysfunction: Methods and outcome. Rosen, Raymond C (Ed); Leiblum, Sandra Risa (Ed) 1992;(1992):378
Anderson RA, Bancroft J, Wu FC. The effects of exogenous testosterone on sexuality and mood of normal men. Journal of Clinical Endocrinology & Metabolism. 1992;75(6):1503-1507. [pmid: 1464655].
Anderson RA, Martin CW, Kung AW, et al. 7Alpha-methyl-19-nortestosterone maintains sexual behavior and mood in hypogonadal men. Journal of Clinical Endocrinology & Metabolism. 1999;84(10):3556-3562. [pmid: 10522995].
Anderson RA, Wallace AM, Sattar N, et al. Evidence for tissue selectivity of the synthetic androgen 7 alpha-methyl-19-nortestosterone in hypogonadal men. Journal of Clinical Endocrinology & Metabolism. 2003;88(6):2784-2793. [pmid: 12788888].
Andersson KE. Pharmacology of penile erection. Pharmacol Rev. 2001;53(3):417-450. [pmid: 11546836].
Andolsek KM. Alprostadil for the treatment of erectile dysfunction. Am Fam Physician. 1997;55(5):1902-1903.
Andriole G, Bruchovsky N, Chung LWK, et al. Dihydrotestosterone and the prostate: The scientific rationale for 5a-reductase inhibitors in the treatment of benign prostatic hyperplasia. Br J Urol. 2004;172(4 I):1399-1403.
Anonymous. Tadalafil: new preparation. Slightly more convenient, but poorly assessed in organic disorders. Prescrire Int 2003;12(68):213–215.
Anonymous. Tadalafil (cialis) for erectile dysfunction. Medical Letter on Drugs & Therapeutics 2003;45(1172):101–102.
Anonymous. First study of Viagra in black men demonstrates effective, well-tolerated treatment. Urol Nurs 2002;22(4):285–286.
Anonymous. Study shows patients taking vardenafil consistently completed sexual intercourse. Urol Nurs 2001;21(6):413–414.
Anonymous. Apomorphine (TAP holdings). 6a beta-aporphine-10,11-diol hydrochloride hemihydrate, apomorphine hydrochloride, spontane, Uprima. Drugs in R & D 1999;2(6):415–416.
Anonymous. Intraurethral alprostadil for impotence. Medical Letter on Drugs & Therapeutics 1997;39(997):32
Anonymous. Treatment for impotence gains FDA approval. Am J Health Syst Pharm 1995;52(19):2078–2079.
Anonymous. Intracavernous injection of alprostadil for erectile dysfunction. Medical Letter on Drugs & Therapeutics 1995;37(958):83–84.
Anonymous. Vardenafil works for 10 hours. Can Pharm J 2005;275(7360):133
Anonymous. Treatment duration of action is important in ED. Can Pharm J 2004;273(7330):878
Anonymous. Dutaseride. Prescrire Int 2004;13(73):183
Anonymous. Erratum: Efficacy and tolerability of sildenafil in Indian males with erectile dysfunction: A double-blind, randomized, placebo controlled, crossover study (Indian Journal of Pharmacology (2004) vol. 37 (5) (317)). Indian J Pharmacol 2004;36(6):391
Anonymous. Partnership struck between Bayer and Schering. Nat Rev Genet 2004;3(10):819
Anonymous. Erectile dysfunction drugs may reduce fertility but help depression. Can Pharm J 2004;272(7294):439
Anonymous. Sildenafil appears safe and effective for some heart failure patients. Can Pharm J 2004;272(7290):310
Anonymous. What to do when oral treatment fails?. Int J Impot Res 2003;15(SUPPL. 7):S30-S32.
Anonymous. Oral drug treatment of erectile dysfunction. Int J Impot Res 2003;15(SUPPL. 7):S27-S29.
Anonymous. Counselling and increased dose of sildenafil improves response in ED. British Journal of Diabetes & Vascular Disease 2003;3(6):445
Anonymous. Improve erectile function early after prostatectomy. Med Today 2003;4(11):8–9.
Anonymous. Recent FDA approval of new erectile dysfunction drug provides first challenge to sildenafil. Geriatrics and Aging 2003;6(8):11
Anonymous. New PDE 5 inhibitor efficacious for erectile dysfunction in diabetics. Cardiology Review 2003;20(10):
Anonymous. Inhaled apomorphine promising for erectile dysfunction treatment. Can Pharm J 2003;271(7261):170
Anonymous. Transurethral alprostadil. Prescrire Int 2002;11(61):144
Anonymous. IDdb News focus. Current Drug Discovery 2003;(pp 10–13):-13.
Anonymous. Sildenafil effective for sexual dysfunction associated with use of antidepressants. Can Pharm J 2003;270(7231):41
Anonymous. Vardenafil prolongs improved erectile function in diabetics. Cardiology Review 2002;19(10):38–39.
Anonymous. Erectile dysfunction treated effectively with tadalafil. Economics of Neuroscience 2001;3(11):19
Anonymous. New erectile dysfunction drug useful in diabetes. Can Pharm J 2001;267(7173):669
Anonymous. Erectile dysfunction - Alprostadil. Manuf Chem Aerosol News 2001;72(11):21
Anonymous. Erectile dysfunction - Vardenafil. Manuf Chem Aerosol News 2001;72(6):25
Anonymous. FDA approves oral therapy for erectile dysfunction. Am J Health Syst Pharm 1998;55(10):981–984.
Anonymous. Sildenafil Viagra(R) UK-92480: Treatment of erectile dysfunction phosphodiesterase V inhibitor. Drugs of the Future 1998;23(2):242–243.
Anonymous. Intracavernosal alprostadil for erectile dysfunction. Hospital Practice (Office Edition) 1996;31(8):136–137.
Anonymous. Intracavernous alprostadil: Effective therapy for erectile dysfunction. Drugs & Therapy Perspectives 1996;7(6):1–5.
Anonymous. Heart drug with ‘viagra side-effect’. Indian J Med Sci 1999;53(5):236
Anonymous. What to do if Viagra won't do. Harvard Mens Health Watch 2005;9(10):4–8.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: intracavernous injection of prostaglandin E1. JAMA 1991;265(24):3321–3323.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: papaverine and phentolamine. JAMA 1990;264(6):752–754.
Ansong KS, Punwaney RB. An assessment of the clinical relevance of serum testosterone level determination in the evaluation of men with low sexual drive. Br J Urol. 1999;162(3 I):719-721.
Ansong KS, Lewis C, Jenkins P, et al. Epidemiology of erectile dysfunction: a community-based study in rural New York State. Ann Epidemiol. 2000;10(5):293-296. [pmid: 10942877].
Arafa M, Eid H, Shamloul R. Significance of phentolamine redosing during prostaglandin E1 penile color Doppler ultrasonography in diagnosis of vascular erectile dysfunction. Int J Urol. 2007;14(5):476-477. [pmid: 17511742].
Araujo AB, O'Donnell AB, Brambilla DJ, et al. Prevalence and incidence of androgen deficiency in middle-aged and older men: Estimates from the Massachusetts male aging study. Journal of Clinical Endocrinology & Metabolism. 2004;89(12):5920-5926. [pmid: 15579737].
Araujo Andre B, Durante Richard, Feldman Henry A, et al. The relationship between depressive symptoms and male erectile dysfunction: Cross-sectional results from the Massachusetts male aging study. Psychosom Med. 1998;60(4):458-465. [pmid: 9710291].
Arnavaz A, Aurich A, Weissenborn K, et al. Effect of sildenafil (Viagra) on cerebral blood flow velocity: a pilot study. Psychiatry Res. 2003;122(3):207-209. [pmid: 12694895].
Arnold R, Beer D, Bhalay G, et al. 8-Aryl xanthines potent inhibitors of phosphodiesterase 5. Bioorg Med Chem Lett. 2002;12(18):2587-2590. [pmid: 12182866].
Aronson JK. Features of this month's Journal. Br J Clin Pharmacol. 2003;55(4):327-328.
Arslan D, Esen AA, Secil M, et al. A new method for the evaluation of erectile dysfunction: sildenafil plus Doppler ultrasonography. Br J Urol. 2001;166(1):181-184.
Arthur R. Cardiovascular disorders and erectile dysfunction. British Journal of Cardiology. 2002;9(3):144-145.
Ashton AK, Jamerson BD, Weinstein WL, et al. Antidepressant-related adverse effects impacting treatment compliance: Results of a patient survey. Current Therapeutic Research, Clinical & Experimental. 2005;66(2):96-106.
Atala A. What's new in urology. J Am Coll Surg. 2004;199(3):446-461. [pmid: 15325616].
Atikeler MK, Gecit I, Senol FA. Optimum usage of prilocaine-lidocaine cream in premature ejaculation. Andrologia. 2002;34(6):356-359. [pmid: 12472618].
Atmaca M, Kuloglu M, Tezcan E. A new atypical antipsychotic: quetiapine-induced sexual dysfunctions. Int J Impot Res. 2005;17(2):201-203. [pmid: 15284834].
Avasthi A, Basu D, Kulhara P, et al. Psychosexual dysfunction in Indian male patients: Revisited after seven years. Arch Sex Behav. 1994;23(6):685-695. [pmid: 7872862].
Aversa A, Mazzilli F, Rossi T, et al. Effects of sildenafil (Viagra) administration on seminal parameters and post-ejaculatory refractory time in normal males. Hum Reprod. 2000;15(1):131-134. [pmid: 10611201].
Aydin S, Unal D, Erol H, et al. Multicentral clinical evaluation of the aetiology of erectile dysfunction: a survey report. International Urology & Nephrology. 2001;32(4):699-703. [pmid: 11989568].
Ayub W, Fletcher S. End-stage renal disease and erectile dysfunction. Is there any hope?. Nephrology Dialysis Transplantation. 2000;15(10):1525-1528.
Bagatell CJ, Heiman JR, Rivier JE, et al. Effects of endogenous testosterone and estradiol on sexual behavior in normal young men.[erratum appears in J Clin Endocrinol Metab 1994 Jun;78(6):1520]. Journal of Clinical Endocrinology & Metabolism. 1994;78(3):711-716. [pmid: 8126146].
Baggaley MR, Hirst JF, Watson JP. Outcome of patients referred to a psychosexual clinic with erectile failure. Sexual & Marital Therapy. 1996;11(2):123-130.
Bai WJ, Zhu JC, Jiang H, et al. [A comparative study of different vasoactive drugs in the treatment of impotence]. Chinese Journal of Urology. 1992;13(6):453-455.
Bailey J, Evans JP, Hardy M, et al. Synopsis: 2005 Annual Meeting of the American Society of Andrology. J Androl. 2005;26(6):678-688. [pmid: 16291961].
Bancroft J, Munoz M, Beard M, et al. The effects of a new alpha-2 adrenoceptor antagonist on sleep and nocturnal penile tumescence in normal male volunteers and men with erectile dysfunction. Psychosom Med. 1995;57(4):345-356. [pmid: 7480564].
Baniel J, Israilov S, Segenreich E, et al. Comparative evaluation of treatments for erectile dysfunction in patients with prostate cancer after radical retropubic prostatectomy. BJU Int. 2001;88(1):58-62. [pmid: 11446847].
Barnas J, Parker M, Guhring P, et al. The utility of tamsulosin in the management of orgasm-associated pain: a pilot analysis.[see comment]. Eur Urol. 2005;47(3):361-365. [pmid: 15716202].
Barqawi A, O'Donnell C, Kumar R, et al. Correlation between LUTS (AUA-SS) and erectile dysfunction (SHIM) in an age-matched racially diverse male population: data from the Prostate Cancer Awareness Week (PCAW). Int J Impot Res. 2005;17(4):370-374. [pmid: 15889121].
Bartlik Barbara D, Kaplan Peter, Kaplan Helen S. Psychostimulants apparently reverse sexual dysfunction secondary to selective serotonin re-uptake inhibitors. J Sex Marital Ther. 1995;21(4):264-271. [pmid: 8789508].
Bayes M, Rabasseda X, Prous JR. Gateways to Clinical Trials. Methods & Findings in Experimental & Clinical Pharmacology. 2004;26(9):723-753. [pmid: 15632957].
bdel-Khalek M, El-Hammady S, Ibrahiem el. A 4-year follow-up of a randomized prospective study comparing transurethral electrovaporization of the prostate with neodymium: YAG laser therapy for treating benign prostatic hyperplasia. BJU Int. 2003;91(9):801-805. [pmid: 12780836].
Beard S, Hunn A, Wight J. Treatments for spasticity and pain in multiple sclerosis: A systematic review. Health Technol Assess. 2003;7(40):111p.
Beasley CM, Mitchell MI, Dmitrienko AA, et al. The combined use of ibutilide as an active control with intensive electrocardiographic sampling and signal averaging as a sensitive method to assess the effects of tadalafil on the human QT interval.[see comment]. J Am Coll Cardiol. 2005;46(4):678-687. [pmid: 16098435].
Becher E, Glina S. Erectile dysfunction in Latin America and treatment with sildenafil citrate (Viagra): Introduction. Int J Impot Res. 2002;14(SUPPL. 2):S1-S2. [pmid: 12161761].
Bella AJ, Brock GB. Tadalafil: A comprehensive update. Journal of Drug Evaluation. 2004;2(8):225-246.
Benson GS. The clinical evaluation of the patient presenting with erectile dysfunction: what is reasonable?. [Review] [27 refs]. Semin Urol. 1990;8(2):94-99. [pmid: 2191404].
Beretta G, Saltarelli O, Marzotto M, et al. Transcutaneous minoxidil in the treatment of erectile dysfunctions in spinal cord injured men. Acta Eur Fertil. 1993;24(1):27-30. [pmid: 8303971].
Bestane WJ, Bestane MC, Ramos NA. Prospective study of sodium nitroprusside in pharmacologically induced erection. Braz J Urol. 2001;27(2):155-158.
Beutel ME, Wiltink J, Hauck EW, et al. Correlations between hormones, physical, and affective parameters in aging urologic outpatients. Eur Urol. 2005;47(6):749-755. [pmid: 15925068].
Bhatia MS, Malik SC. Dhat syndrome—a useful diagnostic entity in Indian culture. Br J Psychiatry. 1991;159(Nov.):691-695. [pmid: 1756347].
Bivalacqua TJ, Hellstrom WJG. Potential application of gene therapy for the treatment of erectile dysfunction. J Androl. 2001;22(2):183-190. [pmid: 11229791].
Black AM, Day AG, Morales A. The reliability of clinical and biochemical assessment in symptomatic late-onset hypogonadism: Can a case be made for a 3-month therapeutic trial?. BJU Int. 2004;94(7):1066-1070. [pmid: 15541129].
Blander DS, Sanchez-Ortiz RF, Broderick GA. Sex inventories: can questionnaires replace erectile dysfunction testing?. Urology. 1999;54(4):719-723. [pmid: 10510935].
Boccon Gibod L. Is transurethral needle ablation a safe and effective treatment for lower urinary tract symptoms secondary to BPH?. Nature Clinical Practice Urology. 2004;1(1):24-25.
Bochinski DJ, Dean RC, Lue TF. Erectile dysfunction and priapism. Nat Clin Pract Urol. 2004;1(1):49-53. [pmid: 16474467].
Bodie JA, Beeman WW, Monga M. Psychogenic erectile dysfunction. Int J Psychiatry Med. 2003;33(3):273-293. [pmid: 15089008].
Bodie J, Lewis J, Schow D, et al. Laboratory evaluations of erectile dysfunction: an evidence based approach. Br J Urol. 2003;169(6):2262-2264.
Bodner DR, Leffler B, Frost F. The role of intracavernous injection of vasoactive medications for the restoration of erection in spinal cord injured males: a three year follow up. Paraplegia. 1992;30(2):118-120. [pmid: 1589286].
Bolona ER, Uraga MV, Haddad RM, et al. Testosterone use in men with sexual dysfunction: a systematic review and meta-analysis of randomized placebo-controlled trials. Mayo Clin Proc. 2007;82(1):20-28. [pmid: 17285782].
Boolell M, Allen MJ, Ballard SA, et al. Sildenafil: an orally active type 5 cyclic GMP-specific phosphodiesterase inhibitor for the treatment of penile erectile dysfunction. Int J Impot Res. 1996;8(2):47-52. [pmid: 8858389].
Boshier A, Wilton LV, Shakir SAW. Evaluation of the safety of sildenafil for male erectile dysfunction: Experience gained in general practice use in England in 1999. BJU Int. 2004;93(6):796-801. [pmid: 15049992].
Bouloux P. Testim 1% testosterone gel for the treatment of male hypogonadism. [Review] [33 refs]. Clin Ther. 2005;27(3):286-298. [pmid: 15878382].
Boydak B, Nalbantgil S, Fici F, et al. A randomised comparison of the effects of nebivolol and atenolol with and without chlorthalidone on the sexual function of hypertensive men. Clinical Drug Investigation. 2005;25(6):409-416. [pmid: 17532681].
Braatvedt GD. Outcome of managing impotence in clinical practice. N Z Med J. 1999;112(1092):272-274. [pmid: 10472891].
Brake M, Loertzer H, Horsch R, et al. Treatment of Peyronie's disease with local interferon-alpha 2b. BJU Int. 2001;87(7):654-657. [pmid: 11350406].
Bratus D, Hlebic G, Hajdinjak T. 16905960 of erectile dysfunction. Croat Med J. 2007;48(1):76-80. [pmid: 17309142].
Brazil M. Viagra for broken hearts?. Nat Rev Genet. 2005;4(3):190.
Brennemann W, Kohler W, Zierz S, et al. Testicular dysfunction in adrenomyeloneuropathy. Eur J Endocrinol. 1997;137(1):34-39. [pmid: 9242199].
Brennemann W, Stitz B, Van Ahlen H, et al. Treatment of idiopathic erectile dysfunction in men with the opiate antagonist naltrexone—a double-blind study. J Androl. 1993;14(6):407-410. [pmid: 8294223].
Briganti A, Chun FKH, Salonia A, et al. A comparative review of apomorphine formulations for erectile dysfunction: Recommendations for use in the elderly. Drugs Aging. 2006;23(4):309-319. [pmid: 16732690].
Briganti A, Salonia A, Gallina A, et al. Drug insight: Oral phosphodiesterase type 5 inhibitors for erectile dysfunction. Nature Clinical Practice Urology. 2005;2(5):239-247.
Briganti A, Salonia A, Zanni G, et al. Erectile dysfunction and radical prostatectomy: An update. Eau Update Series. 2004;2(2):84-92.
Brindis RG, Kloner RA. Sildenafil in patients with cardiovascular disease. [Review] [33 refs]. Am J Cardiol. 2003;92(9A):26M-36M. [pmid: 12842240].
Brixius K, Middeke M, Lichtenthal A, et al. Nitric oxide, erectile dysfunction and beta-blocker treatment (MR NOED study): Benefit of nebivolol versus metoprolol in hypertensive men. Clinical & Experimental Pharmacology & Physiology. 2007;34(4):327-331. [pmid: 17324145].
Broderick GA, Allen G, McClure RD. Vacuum tumescence devices: the role of papaverine in the selection of patients. Br J Urol. 1991;145(2):284-286.
Brooks DP, Giuliano F. Genitourinary diseases. Drug Discovery Today: Therapeutic Strategies. 2005;2(1):iii-iiv.
Brown JS, Wessells H, Chancellor MB, et al. Urologic complications of diabetes. Diabetes Care. 2005;28(1):177-185. [pmid: 15616253].
Buchholz NP, Weuste R, Mattarelli G, et al. Post-vasectomy erectile dysfunction. J Psychosom Res. 1994;38(7):759-762. [pmid: 7877130].
Buddeberg C, Bucher T, Hornung R. [Erectile dysfunction in men in their second half of life]. Urologe 2005;Ausg. A. 44(9):1045–1046, 1048–51.
Buena F, Swerdloff RS, Steiner BS, et al. Sexual function does not change when serum testosterone levels are pharmacologically varied within the normal male range. Fertility & Sterility. 1993;59(5):1118-1123. [pmid: 8486184].
Bukofzer S, Livesey N. Safety and tolerability of apomorphine SL (Uprima). Int J Impot Res. 2001;13(SUPPL. 3):S40-S44. [pmid: 11477491].
Burls A, Gold L, Clark W. Systematic review of randomised controlled trials of sildenafil (Viagra) in the treatment of male erectile dysfunction. Br J Gen Pract. 2001;51(473):1004-1012. [pmid: 11766850].
Burnett AL. Efficacy of tadalafil for the treatment of erectile dysfunction at 24 and 36 hours after dosing: A randomized controlled trial: Editorial comment 2. Urology. 2003;62(1):126.
Burnett AL. Vasoactive pharmacotherapy to cure erectile dysfunction: fact or fiction?. [Review] [45 refs]. Urology. 2005;65(2):224-230. [pmid: 15708027].
Burnett AL. The impact of sildenafil on molecular science and sexual health. Eur Urol. 2004;46(1):9-14. [pmid: 15183543].
Burns-Cox N, Gingell C. The andropause: fact or fiction?. [Review] [49 refs]. Postgrad Med J. 1997;73(863):553-556. [pmid: 9373594].
Buvat J. Hyperprolactinemia and sexual function in men: a short review. [Review] [26 refs]. Int J Impot Res. 2003;15(5):373-377. [pmid: 14562140].
Buvat J, Boujadoue G. Testosterone replacement therapy in the ageing man. The Journal of Mens Health & Gender. 2005;2(4):396-399.
Calof OM, Singh AB, Lee ML, et al. Adverse events associated with testosterone replacement in middle-aged and older men: A meta-analysis of randomized, placebo-controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60(11):1451-1457.
Campbell M. Beneficial cardiovascular effects and safety of sildenafil reported in trio of studies. Cardiology Review. 2001;18(6):27.
Cappelleri JC, Siegel RL, Glasser DB, et al. Relationship between patient self-assessment of erectile dysfunction and the sexual health inventory for men. Clin Ther. 2001;23(10):1707-1719. [pmid: 11726005].
Cara AM, Lopes-Martins RAB, Antunes E, et al. The role of histamine in human penile erection. Br J Urol. 1995;75(2):220-224. [pmid: 7850330].
Carani C, Bancroft J, Granata A, et al. Testosterone and erectile function, nocturnal penile tumescence and rigidity, and erectile response to visual erotic stimuli in hypogonadal and eugonadal men. Psychoneuroendocrinology. 1992;17(6):647-654. [pmid: 1287683].
Carani C, Scuteri A, Marrama P, et al. The effects of testosterone administration and visual erotic stimuli on nocturnal penile tumescence in normal men. Horm Behav. 1990;24(3):435-441. [pmid: 2227854].
Cardenas DD, Ditunno J, Graziani V, et al. Phase 2 trial of sustained-release fampridine in chronic spinal cord injury. Proc Annu Clin Spinal Cord Inj Conf. 2007;45(2):158-168.
Carey MP, Johnson BT. Effectiveness of yohimbine in the treatment of erectile disorder: four meta-analytic integrations. Arch Sex Behav. 1996;25(4):341-360. [pmid: 8836468].
Carey Michael P, Wincze John P, Meisler Andrew W. Sexual dysfunction: Male erectile disorder. Barlow, David H (Ed) 1993;(1993):534
Carosa E, Benvenga S, Trimarchi F, et al. Sexual inactivity results in reversible reduction of LH bioavailability. Int J Impot Res. 2002;14(2):93-99. [pmid: 11979323].
Carson CC. PNU-83757: a new agent for the treatment of erectile dysfunction.[comment]. Curr Urol Rep. 2002;3(6):465-466. [pmid: 12425868].
Carson CC, Burnett AL, Levine LA, et al. The efficacy of sildenafil citrate (Viagra) in clinical populations: an update. Urology. 2002;60(2 Suppl 2):12-27. [pmid: 12414330].
Carson CC, Hatzichristou DG, Carrier S. Erratum: Erectile response with vardenafil in sildenafil nonresponders: A multicentre, double-blind, 12-week, flexible-dose, placebo-controlled erectile dysfunction clinical trial (BJU International (2004) 94 (1301–1309)). BJU Int. 2005;96(3):466.
Carson CC, Rajfer J, Eardley I, et al. The efficacy and safety of tadalafil: an update. BJU Int. 2004;93(9):1276-1281. [pmid: 15180622].
Casella R, Deckart A, Bachmann A, et al. The patient's self-evaluation better predicts the degree of erectile dysfunction than the response to intracavernous alprostadil testing. Urol Int. 2004;72(3):216-220. [pmid: 15084765].
Caspi A, Goldenberg M M. Sildenafil: A new drug treatment for male erectile dysfunction. P & T 1998;23(5):
Cawello W, Schweer H, Dietrich B, et al. Pharmacokinetics of prostaglandin E1 and its main metabolites after intracavernous injection and short-term infusion of prostaglandin E1 in patients with erectile dysfunction. Br J Urol. 1997;158(4):1403-1407.
Cecchi M, Sepich CA, Felipetto R, et al. Vacuum constriction device and topical minoxidil for management of impotence. Arch Esp Urol. 1995;48(10):1058-1059. [pmid: 8588728].
Chaiban JT, Azar ST. Erectile dysfunction in diabetic patients. J Med Liban. 2004;52(4):217-219. [pmid: 16432985].
Chang DW, Wood CG, Kroll SS, et al. Cavernous nerve reconstruction to preserve erectile function following non-nerve-sparing radical retropubic prostatectomy: a prospective study. Keisei Geka. 2003;111(3):1174-1181.
Chatterjee R, Andrews HO, McGarrigle HH, et al. Cavernosal arterial insufficiency is a major component of erectile dysfunction in some recipients of high-dose chemotherapy/chemoradiotherapy for haematological malignancies. Bone Marrow Transplant. 2000;25(11):1185-1189. [pmid: 10849531].
Chatterjee R, Kottaridis PD, McGarrigle HH, et al. Management of erectile dysfunction by combination therapy with testosterone and sildenafil in recipients of high-dose therapy for haematological malignancies. Bone Marrow Transplant. 2002;29(7):607-610. [pmid: 11979311].
Chaudhuri TK, Fink S, Burger RH, et al. Nuclear penogram: Non-invasive technique to monitor and record effect of pharmacologically-induced penile erection in impotence therapy. Urology. 1990;35(1):98. [pmid: 2296828].
Cheitlin MD, Hutter AM, Brindis RG, et al. Use of sildenafil (Viagra) in patients with cardiovascular disease. Circulation. 1999;99(1):168-177. [pmid: 9884398].
Chen CT, Valicenti RK, Lu J, et al. Does hormonal therapy influence sexual function in men receiving 3D conformal radiation therapy for prostate cancer?. Int J Radiat Oncol Biol Phys. 2001;50(3):591-595. [pmid: 11395224].
Chen J, Greenstein A, Kaver I, et al. Use of automatic insulin injector for intracorporeal injection in erectile dysfunction. Br J Urol. 1994;152(2):461-462.
Chen J, Mabjeesh NJ, Greenstein A. Sildenafil versus the vacuum erection device: patient preference. Br J Urol. 2001;166(5):1779-1781.
Chen J, Wollman Y, Chernichovsky T, et al. Effect of oral administration of high-dose nitric oxide donor L-arginine in men with organic erectile dysfunction: results of a double-blind, randomized, placebo-controlled study. BJU Int. 1999;83(3):269-273. [pmid: 10233492].
Chen KC, Minor TX, Rahman NU, et al. The additive erectile recovery effect of brain-derived neurotrophic factor combined with vascular endothelial growth factor in a rat model of neurogenic impotence. BJU Int. 2005;95(7):1077-1080. [pmid: 15839936].
Chen KK, Jiann BP, Lin JSN, et al. Erratum: Efficacy and safety of on- demand oral tadalafil in the treatment of men eith erectile dysfunction in Taiwan: A randomized, double- blind, parallel, placebo- conrolled clinical study (Journal of Sexual Medicine vol. 1 (2)). Br J Sex Med. 2005;2(1):158.
Cheng JYW, Ng EML, Chen RYL, et al. Prevalence of erectile dysfunction in Asian populations: A meta-analysis. Int J Impot Res. 2007;19(3):229-244. [pmid: 16929338].
Chew KK. Prevalence of hypogonadism in the aging male and male erectile dysfunction in Asia-Pacific countries. Asian J Androl. 2003;5(2):171-172.
Chew KK, Stuckey BG. Clinical course of penile fibrosis in intracavernosal prostaglandin E1 injection therapy: a follow-up of 44 patients. Int J Impot Res. 2003;15(2):94-98. [pmid: 12789387].
Chew KK, Stuckey BGA. Use of transurethral alprostadil (MUSE) (prostaglandin E1) for glans tumescence in a patient with penile prosthesis. Int J Impot Res. 2000;12(3):195-196. [pmid: 11045915].
Chew KK, Stuckey BGA, Thompson PL. Erectile dysfunction, sildenafil and cardiovascular risk. Med J Aust. 2000;172(6):279-283. [pmid: 10860094].
Chia S. Management of premature ejaculation—a comparison of treatment outcome in patients with and without erectile dysfunction. Int J Androl. 2002;25(5):301-305. [pmid: 12270028].
Chinegwundoh F, Anie K A. Treatments for priapism in boys and men with sickle cell disease. [Review][16 refs]. Cochrane Database Syst Rev 2004;(4):CD004198
Chiu KC, Cohan P, Martinez D, et al. Adrenal insufficiency after medical therapy for prolactin and adrenocorticotropic hormone co-producing pituitary macroadenoma without hypercortisolism. Endocr Pract. 2001;11(6):443-446.
Chiu YJ, Reid IA. Effect of sildenafil on renin secretion in human subjects. Experimental biology and medicine (Maywood, NJ). 2002;227(8):620-625.
Christ B, Brockmeier D, Hauck EW, et al. Interactions of sildenafil and tacrolimus in men with erectile dysfunction after kidney transplantation. Urology. 2001;58(4):589-593. [pmid: 11597545].
Christ GJ, Melman A. The application of gene therapy to the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):111-112. [pmid: 9647947].
Chue P. Gabapentin treatment for premature ejaculation [3]. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 2004;49(9):644-645. [pmid: 15503740].
Cimentepe E, Unsal A, Saglam R. Randomized clinical trial comparing transurethral needle ablation with transurethral resection of the prostate for the treatment of benign prostatic hyperplasia: results at 18 months. J Endourol. 2003;17(2):103-107. [pmid: 12689404].
Clark C. Erectile dysfunction and other problems. Can Pharm J. 2004;272(7299):608-610.
Clark RV, Hermann DJ, Cunningham GR, et al. Marked Suppression of Dihydrotestosterone in Men with Benign Prostatic Hyperplasia by Dutasteride, a Dual 5a-Reductase Inhibitor. Journal of Clinical Endocrinology & Metabolism. 2004;89(5):2179-2184. [pmid: 15126539].
Claro JA, Passerotti CC, Figueiredo Neto AC, et al. An alternative non-invasive treatment for Peyronie's disease. International Braz J Urol. 2004;30(3):199-204. [pmid: 15689246].
Clough J. CNS-targeted sexual dysfunction drug for men and women. Drug Discov Today. 2002;7(9):492-494. [pmid: 11983559].
Coelho OR. Tolerability and safety profile of sildenafil citrate (Viagra) in Latin American patient populations. Int J Impot Res. 2002;14(Suppl 2):54-59. [pmid: 11896479].
Coker C, Bettocchi C, Pryor J. Caverject, a new licensed prostaglandin preparation for use in erectile dysfunction. J Androl. 1994;15(6 SUPPL.):71S.
Coleman CI, Carabino JM, Vergara CM, et al. Vardenafil. Hosp Formul. 2003;38(3):131-148.
Collazos J, Martinez E, Mayo J, et al. Sexual dysfunction in HIV-infected patients treated with highly active antiretroviral therapy. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2002;31(3):322-326. [pmid: 12439208].
Colp GM, Scroppo FI. Can self-directed pelvic floor exercises improve erectile function?. Nature Clinical Practice Urology. 2005;2(3):128-129.
Conti CR, Pepine CJ, Sweeney M. Efficacy and safety of sildenafil citrate in the treatment of erectile dysfunction in patients with ischemic heart disease. Am J Cardiol. 1999;83(5A):29C-34C.
Contreras LN, Masini AM, Danna MM, et al. Glucocorticoids: their role on gonadal function and LH secretion. Minerva Endocrinol. 1996;21(2):43-46. [pmid: 8968148].
Cooper AJ, Losztyn S, Russell NC, et al. Medroxyprogesterone acetate, nocturnal penile tumescence, laboratory arousal, and sexual acting out in a male with schizophrenia. Arch Sex Behav. 1990;19(4):361-372. [pmid: 2144727].
Cormio L, Nisen H, Ruutu M, et al. Etilefrine in the prevention of prolonged erection after diagnostic pharmacological stimulation. Ann Chir Gynaecol. 1996;85(3):247-250. [pmid: 8950448].
Corona G, Mannucci E, Fisher AD, et al. Effect of hyperprolactinemia in male patients consulting for sexual dysfunction. Br J Sex Med. 2007;4(5):1485-1493.
Corona G, Mannucci E, Petrone L, et al. ANDROTEST: a structured interview for the screening of hypogonadism in patients with sexual dysfunction. Br J Sex Med. 2006;3(4):706-715.
Corona G, Mannucci E, Petrone L, et al. Association of hypogonadism and type II diabetes in men attending an outpatient erectile dysfunction clinic. Int J Impot Res. 2006;18(2):190-197. [pmid: 16136189].
Corona G, Mannucci E, Schulman C, et al. Psychobiologic correlates of the metabolic syndrome and associated sexual dysfunction. Eur Urol. 2006;50(3):595-604. [pmid: 16564129].
Creasey GH. Lecture 6: restoration of male sexual function following spinal cord injury. Int J Impot Res. 2000;12(Suppl 3):S54-S55. [pmid: 11002403].
Crowe SM, Streetman DS. Vardenafil treatment for erectile dysfunction. [Review] [43 refs]. Ann Pharmacother. 2004;38(1):77-85. [pmid: 14742800].
Crum-Cianflone NF, Bavaro M, Hale B, et al. Erectile dysfunction and hypogonadism among men with HIV. AIDS Patient Care & Stds. 2007;21(1):9-19. [pmid: 17263654].
Culha M, Mutlu N, Acar O, et al. Patient-partner satisfaction with intracavernous medication supported with oral agents in selected cases of Peyronie's disease: A ten-month follow-up study. International Urology & Nephrology. 1999;31(2):257-262. [pmid: 10481972].
Curran M, Keating G. Tadalafil.[erratum appears in Drugs. 2003;63(23):2703]. [Review] [31 refs]. Drugs. 2003;63(20):2203-2212. [pmid: 14498756].
Curri SB, Menchini Fabris F. Evidence and results obtained with a new Trans-Epidermal Barrier (T.E.B.) drug in the medical treatment of vascular impotence. Boll Chim Farm. 1996;135(5):316-334. [pmid: 8942060].
Cyranoski D. Malaysian researchers bet big on home-grown Viagra. Nat Med. 2005;11(9):912. [pmid: 16145563].
Czuriga I, Riecansky I, Bodnar J, et al. Comparison of the New Cardioselective Beta-Blocker Nebivolol with Bisoprolol in Hypertension: The Nebivolol, Bisoprolol Multicenter Study (NEBIS). Cardiovascular Drugs & Therapy. 2003;17(3):257-263. [pmid: 14574084].
Dang G, Matern R, Bivalacqua TJ, et al. Intralesional interferon-alpha-2B injections for the treatment of Peyronie's disease. South Med J. 2004;97(1):42-46. [pmid: 14746421].
Davis BE, Weigel JW, Whitford CS. Treatment of male impotence: a new option. Kans Med. 1990;91(12):325-326. [pmid: 1705298].
Davis JM. American College of Neuropsychopharmacology - 43rd annual meeting. 12–16 December 2004, San Juan, Puerto Rico. IDrugs. 2005;8(2):100-103. [pmid: 15696406].
Davis ME, Brewster ME. Cyclodextrin-based pharmaceutics: Past, present and future. Nat Rev Genet. 2004;3(12):1023-1035.
De Meyer JM, Oosterlinck W. Influence of the method of intracavernous injection on penile rigidity: a possible pharmacokinetic explanation. Urology. 1997;49(2):248-252. [pmid: 9037289].
De Tejada I. Vardenafil Duration of Action. Eur Urol. 2006;50(5):901-902. [pmid: 16949729].
De Tejada I, Garvey DS, Schroeder JD, et al. Design and evaluation of nitrosylated alpha-adrenergic receptor antagonists as potential agents for the treatment of impotence. Journal of Pharmacology & Experimental Therapeutics. 1999;290(1):121-128. [pmid: 10381767].
Degirmenci B, Acar M, Albayrak R, et al. Effects of sildenafil citrate (Viagra) on renal arteries: An evaluation with Doppler ultrasound. Urol Int. 2006;77(2):170-172. [pmid: 16888425].
Del Popolo G, Li Marzi V, Mondaini N, et al. Time/duration effectiveness of sildenafil versus tadalafil in the treatment of erectile dysfunction in male spinal cord-injured patients. Proc Annu Clin Spinal Cord Inj Conf. 2004;42(11):643-648.
Delizonna LL, Wincze JP, Litz BT, et al. A comparison of subjective and physiological measures of mechanically produced and erotically produced erections (or, is an erection an erection?). J Sex Marital Ther. 2001;27(1):21-31. [pmid: 11224951].
Denisov MF, Davis JM, Brecher M. Re: Prolactin levels and adverse events in patients treated with risperidone [8] (multiple letters). J Clin Psychopharmacol. 2002;22(5):538-540. [pmid: 12352286].
Derby CA, Araujo AB, Johannes CB, et al. Measurement of erectile dysfunction in population-based studies: the use of a single question self-assessment in the Massachusetts Male Aging Study. Int J Impot Res. 2000;12(4):197-204. [pmid: 11079360].
Derby CA, Barbour MM, Hume AL, et al. Drug therapy and prevalence of erectile dysfunction in the Massachusetts Male Aging Study cohort. Pharmacotherapy. 2001;21(6):676-683. [pmid: 11401181].
Derouet H, Nolden W, Jost WH, et al. Treatment of erectile dysfunction by an external ischiocavernous muscle stimulator. Eur Urol. 1998;34(4):355-359. [pmid: 9748685].
Desouza C, Parulkar A, Lumpkin D, et al. Acute and prolonged effects of sildenafil on brachial artery flow-mediated dilatation in type 2 diabetes. Diabetes Care. 2002;25(8):1336-1339. [pmid: 12145231].
Dietzen CJ, Lloyd LK. Complications of intracavernous injections and penile prostheses in spinal cord injured men. Archives of Physical Medicine & Rehabilitation. 1992;73(7):652-655. [pmid: 1622321].
Dinelli N, Salinitri G, Pomara G, et al. Role of pharmacologic rehabilitation in the recovery of sexual function following radical prostatectomy. Minerva Urol Nefrol. 2005;57(4):325-329. [pmid: 16247354].
Dinsmore WW. Medical treatment of impotence with papaverine and phentolamine intracavernosal injection. Ulster Med J. 1990;59(2):174-176. [pmid: 2278115].
Dinsmore WW, Gingell C, Hackett G, et al. Treating men with predominantly nonpsychogenic erectile dysfunction with intracavernosal vasoactive intestinal polypeptide and phentolamine mesylate in a novel auto-injector system: a multicentre double-blind placebo-controlled study. BJU Int. 1999;83(3):274-279. [pmid: 10233493].
Djavan B, Milani S, Fong YK. Dutasteride: A novel dual inhibitor of 5a-reductase for benign prostatic hyperplasia. Expert Opin Pharmacother. 2005;6(2):311-317. [pmid: 15757426].
Doggrell SA. Comparison of clinical trials with sildenafil, vardenafil and tadalafil in erectile dysfunction. Expert Opin Pharmacother. 2005;6(1):75-84. [pmid: 15709885].
Donatucci CF, Lue TF. Erectile dysfunction in men under 40: etiology and treatment choice. Int J Impot Res. 1993;5(2):97-103. [pmid: 8348217].
Doumas M, Tsakiris A, Douma S, et al. Beneficial effects of switching from beta-blockers to nebivolol on the erectile function of hypertensive patients. Asian J Androl. 2006;8(2):177-182. [pmid: 16491268].
Dundar SO. Visual loss associated with erectile dysfunction drugs. Can J Ophthalmol. 2007;42(1):10-12. [pmid: 17361234].
Dupont Simon. Multiple sclerosis and sexual functioning: A review. Clin Rehabil. 1995;9(2):135-141.
Durackova Z, Trebaticky B, Novotny V, et al. Lipid metabolism and erectile function improvement by Pycnogenol, extract from the bark of Pinus pinaster in patients suffering from erectile dysfunction - A pilot study. Adv Food Nutr Res. 2003;23(9):1189-1198.
Eandi J A, Yao A P, Javidan J. Penile paraffinoma: the delayed presentation. Int Urol Nephrol 2007;
Eardley I. New oral therapies for the treatment of erectile dysfunction. Br J Urol. 1998;81(1):122-127. [pmid: 9467488].
Earle CM, Keogh EJ, Ker JK, et al. The role of intracavernosal vasoactive agents to overcome impotence due to spinal cord injury. Paraplegia. 1992;30(4):273-276. [pmid: 1625897].
Earle CM, Stuckey BG, Ching HL, et al. The incidence and management of priapism in Western Australia: a 16 year audit. Int J Impot Res. 2003;15(4):272-276. [pmid: 12934055].
Edwards G, Muirhead GJ. British Journal of Clinical Pharmacology: Introduction. Br J Clin Pharmacol. 2002;53(SUPPL. 1):1S-3S.
Ekmekcioglu O, Inci M, Demirci D, et al. Effects of sildenafil citrate on ejaculation latency, detumescence time, and refractory period: placebo-controlled, double-blind, crossover laboratory setting study. Urology. 2005;65(2):347-352. [pmid: 15708051].
Ekselius L, Von Knorring L. Effect on sexual function of long-term treatment with selective serotonin reuptake inhibitors in depressed patients treated in primary care. J Clin Psychopharmacol. 2001;21(2):154-160. [pmid: 11270911].
El Malik EMA. Erectile dysfunction: An update of diagnosis and management. Qatar Medical Journal. 2000;9(2):9-17.
El-Bahnasawy MS, El-Assmy A, Dawood A, et al. Effect of the use of internal iliac artery for renal transplantation on penile vascularity and erectile function: A prospective study. Br J Urol. 2004;172(6 I):2335-2339.
El-Rufaie Omer EF, Bener Abdulbari, Abuzeid Mohamed SO, et al. Sexual dysfunction among type II diabetic men: A controlled study. J Psychosom Res. 1997;43(6):605-612. [pmid: 9430073].
El-Sakka AI. Penile axial rigidity and Doppler ultrasonography parameters in patients with erectile dysfunction: association with type 2 diabetes. Urology. 2003;62(3):525-531. [pmid: 12946761].
Emilien G. Alprox-TD NexMed Inc. Current Opinion in Central & Peripheral Nervous System Investigational Drugs. 2000;2(3):311-320.
Ende AR, Lo Re V, DiNubile MJ, et al. Erectile dysfunction in an urban HIV-positive population. AIDS Patient Care & Stds. 2006;20(2):75-78. [pmid: 16475887].
Engelhardt PF, Daha LK, Zils T, et al. Acupuncture in the treatment of psychogenic erectile dysfunction: first results of a prospective randomized placebo-controlled study. Int J Impot Res. 2003;15(5):343-346. [pmid: 14562135].
Engelson ES, Pi-Sunyer FX, Kotler DP. Effects of megestrol acetate therapy on body composition and circulating testosterone concentrations in patients with AIDS. Int J STD AIDS. 1995;9(9):1107-1108.
Engl T, Beecken WD, Wolfram M, et al. Uropharmacology: Current and future strategies in the treatment of erectile dysfunction and benign prostate hyperplasia. International Journal of Clinical Pharmacology & Therapeutics. 2004;42(10):527-533. [pmid: 15516021].
English JC, King DHC, Foley JP. Penile shaft hypopigmentation: Lichen sclerosus occurring after the initiation of alprostadil intracavernous injections for erectile dysfunction. J Am Acad Dermatol. 1998;39(5 I):801-803. [pmid: 9810901].
Ensign C. First-line therapies for erectile dysfunction. [Review] [8 refs]. JAAPA. 2001;14(10):17-20. [pmid: 11715672].
Erdogru T, Kocak T, Serdaroglu P, et al. Evaluation and therapeutic approaches of voiding and erectile dysfunction in neurological Behcet's syndrome. Br J Urol. 1999;162(1):147-153.
Ernst E. Chinese herbal medicines for consumers in the West. Focus on Alternative & Complementary Therapies. 2005;10(2):94-97.
Ernst E, Pittler MH. Yohimbine for erectile dysfunction: a systematic review and meta-analysis of randomized clinical trials. J Urol. 1998;159(2):433-436. [pmid: 9649257].
Escobar-Jimenez F. [Efficacy and safety of sildenafil in men with type 2 diabetes mellitus and erectile dysfunction]. Med Clin (Barc). 2002;119(4):121-124. [pmid: 12106522].
Esposito K, Giugliano F, Martedi E, et al. High proportions of erectile dysfunction in men with the metabolic syndrome. Diabetes Care. 2005;28(5):1201-1203. [pmid: 15855589].
Evans M F. Viagra! Are we ready?. Can Fam Physician. 1998;44:2103-2105. [pmid: 9805164].
Fagan Peter J, Blum Lois H. Issues in the psychotherapeutic treatment of sexual dysfunction following radical retropubic prostatectomy. Rosen, Raymond C (Ed); Leiblum, Sandra R (Ed) 1995;(1995):400
Fagan TC, Buttler S, Marbury T, et al. Cardiovascular safety of sublingual apomorphine in patients on stable doses of oral antihypertensive agents and nitrates. Am J Cardiol. 2001;88(7):760-766. [pmid: 11589843].
Faiman C. Endocrine causes of impotence. Cleve Clin J Med. 1993;60(6):428-429. [pmid: 7507006].
Fazeli-Matin S, Montague DK, Angermeier KW, et al. Penile fracture after intracavernous injection therapy. Br J Urol. 1998;159(6):2094.
Fedele D, Coscelli C, Cucinotta D, et al. Management of erectile dysfunction in diabetic subjects: results from a survey of 400 diabetes centres in Italy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14(5):277-282.
Fedele D, Lamonica M, Bax G. Experience with sildenafil in diabetes. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):49-52.
Fekete F, Fabian E. [Effectiveness and adverse effects of sildenafil in erectile dysfunction]. Orv Hetil. 2000;141(3):115-118. [pmid: 10693332].
Feldman HA, Goldstein I, Hatzichristou DG, et al. Impotence and its medical and psychosocial correlates: results of the Massachusetts Male Aging Study. Br J Urol. 1994;151(1):54-61.
Feldman HA, Johannes CB, Derby CA, et al. Erectile dysfunction and coronary risk factors: prospective results from the Massachusetts male aging study. Prev Med. 2000;30(4):328-338. [pmid: 10731462].
Fink HA, Mac Donald R, Rutks IR, et al. Sildenafil for male erectile dysfunction: a systematic review and meta-analysis. Arch Intern Med. 2002;162(12):1349-1360. [pmid: 12076233].
Fink HA, MacDonald R, Rutks IR, et al. Trazodone for erectile dysfunction: a systematic review and meta-analysis. BJU Int. 2003;92(4):441-446. [pmid: 12930437].
Finkbeiner A. Random musing about a little blue pill. J Ark Med Soc. 1998;95(3):100-101. [pmid: 9735630].
Fishbain David A. Impact of sildenafil on male erectile disorder due to psychological factors. Can J Psychiatry. 2000;45(1):85-86. [pmid: 10696497].
Fisher WA, Rosen RC, Eardley I, et al. The Multinational Men's Attitudes to Life Events and Sexuality (MALES) Study Phase II: Understanding PDE5 inhibitor treatment seeking patterns, among men with erectile dysfunction. Br J Sex Med. 2004;1(2):150-160.
Flack JM. The effect of doxazosin on sexual function in patients with benign prostatic hyperplasia, hypertension, or both.[see comment]. [Review] [47 refs]. Int J Clin Pract. 2002;56(7):527-530. [pmid: 12296615].
Foresta C, Caretta N, Rossato M, et al. Role of androgens in erectile function. Br J Urol. 2004;171(6 Pt 1):2358-2362.
Foulks CJ, Cushner HM. Sexual dysfunction in the male dialysis patient: pathogenesis, evaluation, and therapy. [Review] [105 refs]. Am J Kidney Dis. 1986;8(4):211-222. [pmid: 3532769].
Frank T. Tadalafil (Cialis-Lilly). Consultant Pharmacist. 2004;19(4):280-281.
Frank T. Vardenafil (Levitra-Bayer) GSK. Consultant Pharmacist. 2004;19(4):278-280.
Franzen D, Metha A, Seifert N, et al. Effects of beta-blockers on sexual performance in men with coronary heart disease. A prospective, randomized and double blinded study. Int J Impot Res. 2001;13(6):348-351. [pmid: 11918251].
Fraunfelder F W, Fraunfelder F T. Scientific Challenges in Postmarketing Surveillance of Ocular Adverse Drug Reactions. Am J Ophthalmol 2007;143(1):
Freemantle N. Valuing the effects of sildenafil in erectile dysfunction. Br Med J. 2000;320(7243):1156-1157. [pmid: 10784525].
Freytag SO, Stricker H, Pegg J, et al. Phase I Study of Replication-Competent Adenovirus-Mediated Double-Suicide Gene Therapy in Combination with Conventional-Dose Three-Dimensional Conformal Radiation Therapy for the Treatment of Newly Diagnosed, Intermediate- to High-Risk Prostate Cancer. Cancer Res. 2003;63(21):7497-7506. [pmid: 14612551].
Fu Q, Yao DH, Jiang YQ. Effect of sodium nitroprusside on hemodynamics of corpus cavernosum in Chinese. Asian J Androl. 2001;3(4):311-313. [pmid: 11753478].
Fugl-Meyer AR, Lodnert G, Branholm IB, et al. On life satisfaction in male erectile dysfunction. Int J Impot Res. 1997;9(3):141-148. [pmid: 9315491].
Fulgram PF, Cochran JS, Denman JL, et al. Re: Disappointing initial results with transurethral alprostadil for erectile dysfunction in a urology practice setting [5]. Br J Urol. 1999;162(4):1390.
Gallo L, Perdona S, Autorino R, et al. Recovery of erection after pelvic urologic surgery: our experience. Int J Impot Res. 2005;17(6):484-493. [pmid: 15889123].
Gerstenbluth RE, Maniam PN, Corty EW, et al. Prostate-specific antigen changes in hypogonadal men treated with testosterone replacement. J Androl. 2002;23(6):922-926. [pmid: 12399540].
Ghezzi A, Malvestiti GM, Baldini S, et al. Erectile impotence in multiple sclerosis: A neurophysiological study. J Neurol. 1995;242(3):123-126. [pmid: 7751853].
Giammusso B, Gattuso U, Vanaclocha V, et al. Percutaneous lumbar sympathectomy in the treatment of erectile dysfunction secondary to cavernous adrenergic hypertone: initial results of an original technique. Arch Ital Urol Androl. 2005;77(1):5-9. [pmid: 15906781].
Giampietro O, Ferdeghini M, Cerri M, et al. Evaluation of the hypothalamic-pituitary-testicular interaction in diabetic males. European J Lab Med. 1994;2(2):83-89.
Gillies HC, Roblin D, Jackson G. Coronary and systemic hemodynamic effects of sildenafil citrate: From basic science to clinical studies in patients with cardiovascular disease. Int J Cardiol. 2002;86(23):131-141. [pmid: 12419549].
Ginsberg DL. Gabapentin treatment of premature ejaculation. Primary Psychiatry. 2004;11(12):20-21.
Ginsberg DL. Vardenafil treatment of sertraline-induced sexual dysfunction. Primary Psychiatry. 2004;11(11):23-24.
Ginsberg David L. Sildenafil-dihydrocodeine interaction results in prolonged erections. [References]. Primary Psychiatry. 2003;10(2):23.
Ginzburg R, Wong Y, Fader JS. Effect of bupropion on sexual dysfunction. Ann Pharmacother. 2005;39(12):2096-2099. [pmid: 16288071].
Giuberti A, Picozzi SC, Mazza L, et al. Testosterone supplementation in hypogonadal men: our personal experience. Arch Ital Urol Androl. 2005;77(4):191-193. [pmid: 16444930].
Giuliano F. Control of penile erection by the melanocortinergic system: Experimental evidences and therapeutic perspectives. J Androl. 2004;25(5):683-691. [pmid: 15292097].
Giuliano F, Allard J, Rampin O, et al. Pro-erectile effect of systemic apomorphine: Existence of a spinal site of action. Br J Urol. 2002;167(1):402-406.
Giuliano F, Hultling C, El Masry WS, et al. Randomized trial of sildenafil for the treatment of erectile dysfunction in spinal cord injury. Sildenafil Study Group. Ann Neurol. 1999;46(1):15-21. [pmid: 10401776].
Giuliano F, Pena BM, Mishra A, et al. Efficacy results and quality-of-life measures in men receiving sildenafil citrate for the treatment of erectile dysfunction. Qual Life Res. 2001;10(4):359-369. [pmid: 11763248].
Giuliano Francois, Pena Beatrice, Mishra Avanish, et al. "Efficacy results and quality-of-life measures in men receiving sildenafil citrate for the treatment of erectile dysfunction": Erratum. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care & Rehabilitation. 2002;11(6):613-670.
Gladh YM, Rahgozar M, Hammar ML, et al. Prevalence of symptoms possibly related to PADAM, in a Swedish population aged 55, 65 and 75 years. Maturitas. 2005;50(3):161-166. [pmid: 15734596].
Glasser SP. Revisiting erectile dysfunction in cardiovascular patients. Cardiology Review. 2003;20(12):42-43.
Glasser SP. Safety of PDE 5 inhibition in patients with cardiovascular disease. Cardiology Review. 2002;19(11):32-33.
Glenn DRJ, McClure N, Lewis SEM. The hidden impact of diabetes on male sexual dysfunction and fertility. Hum Fertil. 2003;6(4):174-179.
Goldenberg MM. Safety and efficacy of sildenafil citrate in the treatment of male erectile dysfunction. Clin Ther. 1998;20(6):1033-1048. [pmid: 9916601].
Goldstein I. Oral phentolamine: an alpha-1, alpha-2 adrenergic antagonist for the treatment of erectile dysfunction. [Review][9 refs]. Int J Impot Res 2000;12Suppl-80.
Gontero P, Fontana F, Zitella A, et al. A prospective evaluation of efficacy and compliance with a multistep treatment approach for erectile dysfunction in patients after non-nerve sparing radical prostatectomy. BJU Int. 2005;95(3):359-365. [pmid: 15679794].
Gore JL, Swerdloff RS, Rajfer J. Androgen deficiency in the etiology and treatment of erectile dysfunction. Urol Clin North Am. 2005;32(4):457-468. [pmid: 16291037].
Govier FE, McClure RD, Kramer-Levien D. Endocrine screening for sexual dysfunction using free testosterone determinations. Br J Urol. 1996;156(2 Pt 1):405-408.
Graul A, Castaner J. Phentolamine Mesilate. Treatment of erectile dysfunction. Drugs of the Future. 1998;23(7):725-728.
Graul AI. Latest findings on the diagnosis and treatment of erectile dysfunction. Drug News Perspect. 1996;9(9):572-575.
Gray PB, Singh AB, Woodhouse LJ, et al. Dose-dependent effects of testosterone on sexual function, mood, and visuospatial cognition in older men. Journal of Clinical Endocrinology & Metabolism. 2005;90(7):3838-3846. [pmid: 15827094].
Greco E, Balbi PP, Virag R. Self intra-cavernous injections as a successful treatment in pure neurogenic impotence. Riv Neurol. 1991;61(1):35-38. [pmid: 1857921].
Green HJ, Pakenham KI, Headley BC, et al. Coping and health-related quality of life in men with prostate cancer randomly assigned to hormonal medication or close monitoring. Psychooncology. 2002;11(5):401-414. [pmid: 12228873].
Green JSA, Holden STR, Ingram P, et al. An investigation of erectile dysfunction in Gwent, Wales. BJU Int. 2001;88(6):551-553. [pmid: 11678749].
Greenstein A, Plymate SR, Katz PG. Visually stimulated erection in castrated men. Br J Urol. 1995;153(3:Pt 1):t-2.
Gresser U, Gleiter CH. Erectile dysfunction: comparison of efficacy and side effects of the PDE-5 inhibitors sildenafil, vardenafil and tadalafil—review of the literature. [Review] [92 refs]. Eur J Med Res. 2002;7(10):435-446. [pmid: 12435622].
Gross AJ, Sauerwein DH, Kutzenberger J, et al. Penile prostheses in paraplegic men. Br J Urol. 1996;78(2):262-264. [pmid: 8813925].
Grover JK, Vats V, Ajeeta. Sildenafil (Viagra(TM)). Medico-Legal Update. 1998;3(12):67-78.
Grugni G, Carani C, Maestroni G, et al. Melatonin levels in psychogenic impotence. Hormone & Metabolic Research. 1994;26(9):440-441. [pmid: 7835831].
Grunwald JE, Jacob SS, Siu K, et al. Acute effects of sildenafil citrate (Viagra) on intraocular pressure in open-angle glaucoma. Am J Ophthalmol. 2001;132(6):872-874. [pmid: 11730651].
Gryglewska B, Grodzicki T. Betaxolol in elderly patients in primary care. New Medicine. 2003;6(4):108-111.
Guay AT, Sabharwal P, Varma S, et al. Delayed diagnosis of psychological erectile dysfunction because of the presence of macroprolactinemia. Journal of Clinical Endocrinology & Metabolism. 1996;81(7):2512-2514. [pmid: 8675569].
Guay DRP. Geriatric pharmacotherapy updates. American Journal Geriatric Pharmacotherapy. 2004;2(1):81-87.
Guirguis W R, Maytom M C, Orr M et al. SILDENAFIL FOR ERECTILE DYSFUNCTION - A ONE-YEAR STUDY. 151st Annual Meeting of the American Psychiatric Association 1998;Toronto, Ontario, Canada. 30th May-4th June. 1998. Issue No. 63, 1998.
Guo YL, Zhu JC, Pan TM, et al. Efficacy and safety of oral sildenafil in the treatment of erectile dysfunction. Chinese Journal of Urology. 2001;22(7):389-394.
Gupta N, Sawlani KK, Tripathi A K. Appropriate use of sildenafil citrate in male erectile dysfunction.[see comment]. [Review] [52 refs]. J Assoc Physicians India. 2001;49:889-896. [pmid: 11837756].
Gupta S, Salimpour P, Saenz de, et al. A possible mechanism for alteration of human erectile function by digoxin: inhibition of corpus cavernosum sodium/potassium adenosine triphosphatase activity. Br J Urol. 1998;159(5):1529-1536.
Hackett GI. The treatment of patients with diabetes. Int J STD AIDS. 1996;7(Suppl 3):24-26. [pmid: 8876378].
Haensel SM, Klem TM, Hop WC, et al. Fluoxetine and premature ejaculation: a double-blind, crossover, placebo-controlled study. J Clin Psychopharmacol. 1998;18(1):72-77. [pmid: 9472846].
Haensel SM, Rowland DL, Kallan KT. Clomipramine and sexual function in men with premature ejaculation and controls. Br J Urol. 1996;156(4):1310-1315.
Hamed S, Mohamed K, El-taher A, et al. The sexual and reproductive health in men with generalized epilepsy: A multidisciplinary evaluation. Int J Impot Res. 2006;18(3):287-295. [pmid: 16254569].
Hammadeh MY, Philp T. Transurethral electrovaporization of the prostate (TUVP) is effective, safe and durable. [Review] [28 refs]. Prostate Cancer & Prostatic Diseases. 2003;6(2):121-126. [pmid: 12806369].
Hammadeh MY, Madaan S, Hines J, et al. 5-year outcome of a prospective randomized trial to compare transurethral electrovaporization of the prostate and standard transurethral resection. Urology. 2003;61(6):1166-1171. [pmid: 12809891].
Hanash KA. Comparative results of goal oriented therapy for erectile dysfunction. Br J Urol. 1997;157(6):2135-2138.
Harman SM. Testosterone, Sexuality, and Erectile Function in Aging Men. J Androl. 2003;24(6 SUPPL.):S42-S45. [pmid: 14581494].
Hartmann Uwe, Langer Dieter. Combination of psychosexual therapy and intrapenile injections in the treatment of erectile dysfunctions: Rationale and predictors of outcome. J Sex Educ Ther. 1993;19(1):1-12.
Harwood PJ, Grotz M, Eardley I, et al. Erectile dysfunction after fracture of the pelvis. Journal of Bone & Joint Surgery - British Volume. 2005;87(3):281-290.
Haslam MT. A trial of idazoxan and yohimbine in erectile dysfunction. Sex Marital Ther. 1992;7(3):261-266.
Hatzichristou D G. Sildenafil citrate: lessons learned from 3 years of clinical experience. [Review][60 refs]. Int J Impot Res 2002;14Suppl-52.
Hatzichristou D G. Current treatment and future perspectives for erectile dysfunction. [Review][85 refs]. Int J Impot Res 1998;10Suppl-13.
Hatzimouratidis K, Hatzichristou D. Testosterone and erectile function: an unresolved enigma. Eur Urol. 2007;52(1):26-28. [pmid: 17379397].
Hatzimouratidis K, Hatzichristou D. Phosphodiesterase Type 5 Inhibitors: The Day After. Eur Urol. 2007;51(1):75-89. [pmid: 16949200].
Hatzimouratidis K, Hatzichristou DG. A comparative review of the options for treatment of erectile dysfunction: Which treatment for which patient?. Drugs. 2005;65(12):1621-1650. [pmid: 16060698].
Hawton Keith, Catalan Jose, Fagg Joan. Sex therapy for erectile dysfunction: Characteristics of couples, treatment outcome, and prognostic factors. Arch Sex Behav. 1992;21(2):161-175. [pmid: 1580787].
Hazell P. Review of new compounds available in Australia for the treatment of attention-deficit hyperactivity disorder. Australasian Psychiatry. 2004;12(4):369-375. [pmid: 15715810].
He XQ, Hong BF, Wang XX, et al. Evaluation of efficacy and safety of oral sildenafil citrate therapy for men with erectile dysfunction. Pharmaceutical Journal of Chinese Peoples Liberation Army. 2002;18(4):205-208.
Heaton J. New classification system for erectile dysfunction therapies. J Androl. 1998;19(4):399-404. [pmid: 9733141].
Heaton JP. Key issues from the clinical trials of apomorphine SL. World J Urol. 2001;19(1):25-31. [pmid: 11289567].
Heaton JPW, Altwein JE. The role of apomorphine SL in the treatment of male erectile dysfunction. BJU International - Supplement. 2001;88(3):36-38.
Heaton JPW, Wagner Porst, Eid Wyllie. Apomorphine: An update of clinical trial results. Int J Impot Res. 2000;12(SUPPL. 4):S67-S73. [pmid: 11035390].
Heaton JP, Dean J, Sleep DJ. Sequential administration enhances the effect of apomorphine SL in men with erectile dysfunction. Int J Impot Res. 2002;14(1):61-64. [pmid: 11896482].
Hellstrom WJG, Kendirci M. Type 5 Phosphodiesterase Inhibitors: Curing Erectile Dysfunction. Eur Urol. 2006;49(6):942-945. [pmid: 16563607].
Hellstrom WJ, Overstreet JW, Yu A, et al. Tadalafil has no detrimental effect on human spermatogenesis or reproductive hormones.[see comment]. Br J Urol. 2003;170(3):887-891.
Hellstrom Wayne JG, Egan Robert A, McGee Hall T, et al. "Visual field defect and intracerebral hemorrhage associated with use of vardenafil (Levitra)": Comment and Reply. [References]. Neurology. 2006;66(2):293-294. [pmid: 16434684].
Herrmann HC, Chang G, Klugherz BD, et al. Hemodynamic effects of sildenafil in men with severe coronary artery disease.[see comment]. N Engl J Med. 2000;342(22):1622-1626. [pmid: 10833207].
Hirshkowitz M, Moore CA, O'Connor S, et al. Androgen and sleep-related erections. J Psychosom Res. 1997;42(6):541-546. [pmid: 9226601].
Hirst JF, Watson JP. Referrals aged 60+ to an inner-city psychosexual dysfunction clinic. Sexual & Marital Therapy. 1996;11(2):131-146.
Hofner K, Claes H, De Reijke TM, et al. Tamsulosin 0.4 mg once daily: effect on sexual function in patients with lower urinary tract symptoms suggestive of benign prostatic obstruction. Eur Urol. 1999;36(4):335-341. [pmid: 10473995].
Hollander JB, Gonzalez J, Norman T. Patient satisfaction with pharmacologic erection program. Urology. 1992;39(5):439-441. [pmid: 1580034].
Holt S. Natural approaches to promote sexual function: Part 1: Viagra versus a natural approach. Alternative & Complementary Therapies. 1999;5(4):204-208.
Holtkamp M, Weissinger F, Meierkord H. Erectile dysfunction with topiramate. Epilepsia. 2005;46(1):166-167. [pmid: 15660786].
Hong B, Ji YH, Hong JH, et al. A double-blind crossover study evaluating the efficacy of korean red ginseng in patients with erectile dysfunction: a preliminary report.[see comment]. Br J Urol. 2002;168(5):2070-2073.
Hopps CV, Mulhall JP. Novel agents for sexual dysfunction. BJU Int. 2003;92(6):534-538. [pmid: 14511028].
Horita H, Sato Y, Adachi H, et al. Effects of levodopa on nocturnal penile tumescence: a preliminary study. J Androl. 1998;19(5):619-624. [pmid: 9796623].
Howes OD, Wheeler MJ, Pilowsky LS, et al. Sexual function and gonadal hormones in patients taking antipsychotic treatment for schizophrenia or schizoaffective disorder. Hillside J Clin Psychiatry. 2007;68(3):361-367.
Howes Oliver D, Smith Shubulade, Aitchison Kathy JE. Comments on "Prolactin Levels and Erectile Function in Patients Treated With Risperidone." [References]. J Clin Psychopharmacol. 2005;25(4):393-394. [pmid: 16012288].
Huang ST, Hsieh ML. Different hemodynamic responses by color Doppler ultrasonography studies between sildenafil non-responders and responders. Asian J Androl. 2007;9(1):129-133. [pmid: 17187164].
Huang WJ, Chen KK, Chang LS. Correlation between voiding and erectile function in patients with symptomatic benign prostatic hyperplasia. Journal of the Chinese Medical Association: JCMA. 2005;68(4):178-182. [pmid: 15850068].
Hubler J, Szanto A, Konyves K. Methylene blue as a means of treatment for priapism caused by intracavernous injection to combat erectile dysfunction. International Urology & Nephrology. 2003;35(4):519-521. [pmid: 15198160].
Hultling C. Partners' perceptions of the efficacy of sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Clin Pract 1999;Supplement.102–108.
Hummel S, Paisley S, Morgan A, et al. Clinical and cost-effectiveness of new and emerging technologies for early localised prostate cancer: A systematic review. Health Technol Assess. 2003;7(33):157p.
Hunter R H, Joy C B, Kennedy E et al. Risperidone versus typical antipsychotic medication for schizophrenia.[update of Cochrane Database Syst Rev. 2000;(2):CD000440; PMID: 10796543]. [Review][105 refs]. Cochrane Database Syst Rev 2003;(2):CD000440
Hyer SL, Duckworth K, Jones C. Managing erectile disorders in diabetes: The one stop andrology clinic. Practical Diabetes International. 1998;15(8):225-226.
Isidori AM, Giannetta E, Gianfrilli D, et al. Effects of testosterone on sexual function in men: results of a meta-analysis. Clin Endocrinol (Oxf). 2005;63(4):381-394. [pmid: 16181230].
Israilov S, Baniel J, Shmueli J, et al. Treatment program for erectile dysfunction in patients with cardiovascular diseases. Am J Cardiol. 2004;93(6):689-693. [pmid: 15019870].
Jackson G. Erectile dysfunction and cardiovascular disease.[see comment]. [Review] [46 refs]. Int J Clin Pract. 1999;53(5):363-368. [pmid: 10695101].
Jackson G. Treatment of erectile dysfunction in patients with cardiovascular disease: Guide to drug selection. Drugs. 2004;64(14):1533-1545. [pmid: 15233591].
Jackson G. Vardenafil - PDE5 inhibitor number 3. Int J Clin Pract. 2004;58(3):229. [pmid: 15117087].
Jackson G. PDE5 inhibitors: Looking beyond ED. Int J Clin Pract. 2003;57(3):159-160. [pmid: 12723713].
Jackson G. Sildenafil (Viagra): New data, new confidence in treating erectile dysfunction in the cardiovascular patient. Int J Clin Pract. 2002;56(2):75. [pmid: 11926708].
Jackson G. Phosphodiesterase 5 inhibition: Effects on the coronary vasculature. Int J Clin Pract. 2001;55(3):183-188. [pmid: 11351772].
Jackson G. The metabolic syndrome and erectile dysfunction: multiple vascular risk factors and hypogonadism. Eur Urol. 2006;50(3):426-427. [pmid: 16644094].
Jackson G, Montorsi P, Cheitlin MD. Cardiovascular safety of sildenafil citrate (Viagra): an updated perspective. [Review] [52 refs]. Urology. 2006;68(3 Suppl):47-60. [pmid: 17011375].
Jackson G, Sweeney M, Osterloh IH. Sildenafil citrate (Viagra(TM)): A cardiovascular overview. British Journal of Cardiology. 1999;6(6):325-334.
Jain P, Rademaker AW, McVary KT. Testosterone supplementation for erectile dysfunction: results of a meta-analysis. Br J Urol. 2000;164(2):371-375.
James J S. Frequent urination, leg cramps, leg weakness, erection difficulties: HIV myelopathy amino acid study. AIDS Treat News 2000;(344):3–4.
Jani AB. The effectiveness of combining hormone therapy and radiotherapy in the treatment of prostate cancer. Expert Opin Pharmacother. 2004;5(12):2469-2477. [pmid: 15571465].
Jani AB, Kao J, Heimann R, et al. Hormone therapy and radiotherapy for early prostate cancer: A utility-adjusted number needed to treat (NNT) analysis. Int J Radiat Oncol Biol Phys. 2005;61(3):687-694. [pmid: 15708246].
Jarow JP, Nana-Sinkam P, Sabbagh M, et al. Outcome analysis of goal directed therapy for impotence. Br J Urol. 1996;155(5):1609-1612.
Jeong SJ, Park K, Moon JD, et al. Bicycle saddle shape affects penile blood flow. Int J Impot Res. 2002;14(6):513-517. [pmid: 12494288].
Jiann BP, Yu CC, Su CC. Impact of introduction of sildenafil on other treatment modalities for erectile dysfunction: A study of nationwide and local hospital sales. Int J Impot Res. 2004;16(6):527-530. [pmid: 15229626].
Jordan GH. What's new in urology. J Am Coll Surg. 2003;197(3):444-457. [pmid: 12946801].
Kadioglu A, Erdogru T, Tellaloglu S. Evaluation of penile arteries in papaverine-induced erection with color Doppler ultrasonography. Arch Esp Urol. 1995;48(6):654-658. [pmid: 7661649].
Kamel HK, Morley JE. The management of erectile dysfunction. Reproductive Medicine Review. 2001;9(1):35-47.
Kang BJ, Lee SJ, Kim MD, et al. A placebo-controlled, double-blind trial of Ginkgo biloba for antidepressant-induced sexual dysfunction. Hum Psychopharmacol. 2002;17(6):279-284. [pmid: 12404672].
Kaplan SA, Meehan AG, Shah A. The age related decrease in testosterone is significantly exacerbated in obese men with the metabolic syndrome. What are the implications for the relatively high incidence of erectile dysfunction observed in these men?. Br J Urol. 2006;176(4 Pt 1):1524-1527.
Karlawish JH, Casarett D. Sildenafil for diabetic men with erectile dysfunction.[comment]. JAMA. 1999;282(10):940-941. [pmid: 10485673].
Kassouf W, Carrier S. A comparison of the International Index of Erectile Function and erectile dysfunction studies. BJU Int. 2003;91(7):667-669. [pmid: 12699481].
Kaufman JM, Hatzichristou DG, Mulhall JP, et al. Impotence and chronic renal failure: a study of the hemodynamic pathophysiology. Br J Urol. 1994;151(3):612-618.
Keijzers GB. Aviptadil (Senatek). [Review] [36 refs]. Curr Opin Investig Drugs. 2001;2(4):545-549.
Keles I, Aydin G, Orkun S, et al. Two clinical problems in elderly men: osteoporosis and erectile dysfunction. Arch Androl. 2005;51(3):177-184. [pmid: 16025856].
Kell P. Cardiovascular safety of sildenafil. Int J STD AIDS. 2002;13(7):439-443. [pmid: 12171661].
Keoghane SR, Sullivan ME, Miller MAW. The aetiology, pathogenesis and management of priapism. BJU Int. 2002;90(2):149-154. [pmid: 12081756].
Kerfoot WW, Park HY, Schwartz LB, et al. Characterization of calcium channel blocker induced smooth muscle relaxation using a model of isolated corpus cavernosum. Br J Urol. 1993;150(1):249-252.
Kernohan AF, McIntyre M, Hughes DM, et al. An oral yohimbine/L-arginine combination (NMI 861) for the treatment of male erectile dysfunction: a pharmacokinetic, pharmacodynamic and interaction study with intravenous nitroglycerine in healthy male subjects. Br J Clin Pharmacol. 2005;59(1):85-93. [pmid: 15606445].
Khalaf IM, Levinson IP. Erectile dysfunction in the Africa/Middle East Region: Epidemiology and experience with sildenafil citrate (Viagra). Int J Impot Res. 2003;15(SUPPL. 1):S1-S2. [pmid: 12825101].
Khan LA. Sildenafil citrate (Viagra). JK Pract. 2001;8(1):52-53.
Khan MA, Raistrick M, Mikhailidis DP, et al. MUSE: clinical experience. Current Medical Research & Opinion. 2002;18(2):64-67. [pmid: 12017211].
Kilic S, Ergin H, Baydinc YC. Venlafaxine extended release for the treatment of patients with premature ejaculation: a pilot, single-blind, placebo-controlled, fixed-dose crossover study on short-term administration of an antidepressant drug. Int J Androl. 2005;28(1):47-52. [pmid: 15679621].
Kilic S, Salih M, Anafarta K, et al. Adenosine: a new agent in the diagnosis of impotence. Int J Impot Res. 1994;6(4):191-198. [pmid: 7795719].
Kim JM, Joh YD, Huh JD, et al. Doppler sonography of the penile cavernosal artery: comparison of intraurethral instillation and intracorporeal injection of prostaglandin E1. J Clin Ultrasound. 2001;29(5):273-278. [pmid: 11486321].
Kim NN. Phosphodiesterase type 5 inhibitors: A biochemical and clinical correlation survey. Int J Impot Res. 2003;15(SUPPL. 5):S13-S19. [pmid: 14551572].
Kim NN, Dhir V, Azadzoi KM, et al. Pilot study of the endothelin-A receptor selective antagonist BMS-193884 for the treatment of erectile dysfunction. J Androl. 2001;23(1):76-83. [pmid: 11780926].
Kim SC, Seo KK, Lee SK, et al. Comparison of the synergistic effects of tamsulosin versus phentolamine on penile erection: In vitro and in vivo studies. Urol Res. 1999;27(6):437-444. [pmid: 10651132].
Kim SC, Seo KK, Park BD, et al. Risk factors for an early increase in dose of vasoactive agents for intracavernous pharmacotherapy. Urol Int. 2000;65(4):204-207. [pmid: 11112870].
Kimoto Y, Sakamoto S, Fujikawa K, et al. Up-titration of vardena fi l dose from 10 mg to 20 mg improved erectile function in men with spinal cord injury. Int J Urol. 2006;13(11):1428-1433. [pmid: 17083398].
Kirby RS. Report from London. Prostate Cancer & Prostatic Diseases. 2005;8(4):299. [pmid: 16319940].
Kirby RS, Andersen M, Gratzke P, et al. A combined analysis of double-blind trials of the efficacy and tolerability of doxazosin-gastrointestinal therapeutic system, doxazosin standard and placebo in patients with benign prostatic hyperplasia. BJU Int. 2001;87(3):192-200. [pmid: 11167641].
Kirby RS, O'Leary MP, Carson C. Efficacy of extended-release doxazosin and doxazosin standard in patients with concomitant benign prostatic hyperplasia and sexual dysfunction. BJU Int. 2005;95(1):103-109. [pmid: 15638905].
Kiriakova N, Kiriakov A, Schneider E, et al. Therapeutic effect of essential phospholipids on functional sexual disorders in males. Journal of the European Academy of Dermatology & Venereology. 1998;11(2):191-193. [pmid: 9784056].
Kleinberg DL, Davis JM, De Coster R, et al. Prolactin levels and adverse events in patients treated with risperidone.[see comment]. J Clin Psychopharmacol. 1999;19(1):57-61. [pmid: 9934944].
Kley HK, Stremmel W, Kley JB, et al. Testosterone treatment of men with idiopathic hemochromatosis. Clin Investig. 1992;70(7):566-572.
Kloner RA. Cardiovascular risk and sildenafil. [Review] [27 refs]. Am J Cardiol. 2000;86(2A):57F-61F.
Kloner RA, Zusman RM. Cardiovascular effects of sildenafil citrate and recommendations for its use. [Review] [21 refs]. Am J Cardiol. 1999;84(5B):11N-17N.
Kloner RA, Brindis RG, Cheitlin MD, et al. Roundtable discussion: Tadalafil study group. Am J Cardiol. 2003;92(9 SUPPL. 1):58M-65M.
Kloner RA, Hutter AM, Emmick JT, et al. Time course of the interaction between tadalafil and nitrates.[see comment]. J Am Coll Cardiol. 2003;42(10):1855-1860. [pmid: 14642699].
Kloner RA, Jackson G, Emmick JT, et al. Interaction between the phosphodiesterase 5 inhibitor, tadalafil and 2 alpha-blockers, doxazosin and tamsulosin in healthy normotensive men. Br J Urol. 2004;172(5:Pt 1):t-40.
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil in patients on common antihypertensive therapies. [Review] [5 refs]. Am J Cardiol. 2003;92(9A):47M-57M. [pmid: 12842244].
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil. [Review] [12 refs]. Am J Cardiol. 2003;92(9A):37M-46M.
Klotz T, Mathers MJ, Braun M, et al. Effectiveness of oral L-arginine in first-line treatment of erectile dysfunction in a controlled crossover study. Urol Int. 1999;63(4):220-223. [pmid: 10743698].
Knegtering R, Castelein S, Bous H, et al. A Randomized Open-Label Study of the Impact of Quetiapine Versus Risperidone on Sexual Functioning. J Clin Psychopharmacol. 2004;24(1):56-61. [pmid: 14709948].
Knispel HH. Penile venous surgery in impotence: results in highly selected cases. Urol Int. 1991;47(3):144-148. [pmid: 1771702].
Knoll LD, Benson RC, Bilhartz DL, et al. A randomized crossover study using yohimbine and isoxsuprine versus pentoxifylline in the management of vasculogenic impotence. Br J Urol. 1996;155(1):144-146.
Kobayashi T, Okuno H, Nishiyama H, et al. Adult-onset idiopathic hypogonadotropic hypogonadism presented with erectile and ejaculatory disorder. Int J Urol. 2002;9(10):604-606. [pmid: 12445243].
Kramer-Levien D J. Papaverine—the medical implant. AUAA J 1987;7(4):13-Jun.
Krause W, Mueller U, Mazur A. Measurement of steroid levels in saliva in a population-based survey of lifestyle, medical conditions, marriage, sex life and hormone status in aging men: A feasibility study. Aging Male. 2002;5(4):203-215. [pmid: 12630067].
Kriston L, Harms A, Berner MM. A meta-regression analysis of treatment effect modifiers in trials with flexible-dose oral sildenafil for erectile dysfunction in broad-spectrum populations. Int J Impot Res. 2006;18(6):559-565. [pmid: 16688210].
Kromann-Andersen B. Intracavernosal pharmacotherapy with injection pen. Lancet. 1988;1(85756):54-59. [pmid: 2891913].
Kuba R, Pohanka M, Zakopcan J, et al. Sexual dysfunctions and blood hormonal profile in men with focal epilepsy. Epilepsia. 2006;47(12):2135-2140. [pmid: 17201714].
Kukreja RC, Ockaili R, Salloum F, et al. Cardioprotection with phosphodiesterase-5 inhibition - A novel preconditioning strategy. Journal of Molecular & Cellular Cardiology. 2004;36(2):165-173. [pmid: 14871543].
Kunelius P, Hakkinen J, Lukkarinen O. Is high-dose yohimbine hydrochloride effective in the treatment of mixed-type impotence? A prospective, randomized, controlled double-blind crossover study. Urology. 1997;49(3):441-444. [pmid: 9123711].
Kupecz D. Alprostadil for the treatment of erectile dysfunction. J Am Acad Nurse Pract. 1996;21(5):143-145.
Kupelian V, Shabsigh R, Travison TG, et al. Is there a relationship between sex hormones and erectile dysfunction? Results from the Massachusetts Male Aging Study. Br J Urol. 2006;176(6 Pt 1):2584-2588.
Kvistborg A, Halse J, Bakke S, et al. Long-term treatment of macroprolactinomas with CV 205-502. Acta Endocrinol (Copenh). 1993;128(4):301-307. [pmid: 8098891].
La Pera G, Franco Giannotti C, Taggi F, et al. Prevalence of sexual disorders in those young males who later become drug abusers. J Sex Marital Ther. 2003;29(2):149-156. [pmid: 12623766].
La Vignera S, Calogero AE, Cannizzaro MA, et al. Erectile vascular dysfunction and analysis of the risk factors related to it. Clinical experience. Minerva Endocrinol. 2007;32(1):17-21. [pmid: 17353863].
Labbate Lawrence A. "Sex and serotonin reuptake inhibitor antidepressants": Erratum. Psychiatr Ann. 1999;29(12):683.
Labbate Lawrence A, Croft Harry A, Oleshansky Marvin AE. Antidepressant-Related Erectile Dysfunction: Management via Avoidance, Switching Antidepressants, Antidotes, and Adaptation. [References]. Hillside J Clin Psychiatry. 2003;64(Suppl 10):11-19.
Labbate Lawrence A, Grimes Jamie, Hines Alan, et al. Sexual dysfunction induced by serotonin reuptake antidepressants. J Sex Marital Ther. 1998;24(1):3-12. [pmid: 9509375].
Lamberg L. New drug for erectile dysfunction boon for many, ‘viagravation’ for some. J Am Med Assoc. 1998;280(10):867-869.
Larson TR. Current treatment options for benign prostatic hyperplasia and their impact on sexual function. Urology. 2003;61(4):692-698. [pmid: 12670545].
Lasaponara F, Paradiso M, Milan MG, et al. Erectile dysfunction after kidney transplantation: our 22 years of experience.[see comment]. Transplant Proc. 2004;36(3):502-504. [pmid: 15110572].
Laties A, Sharlip I. Ocular safety in patients using sildenafil citrate therapy for erectile dysfunction. [Review] [81 refs]. Br J Sex Med. 2006;3(1):12-27.
Laties AM, Zrenner E. Viagra (sildenafil citrate) and ophthalmology. Progress in Retinal & Eye Research. 2002;21(5):485-506. [pmid: 12207947].
Laties A M, Fraunfelder F T, Flach A J et al. Ocular safety of Viagra, (sildenafil citrate). Trans Am Ophthalmol Soc 1999;97(pp 115–128):-128.
Latini DM, Penson DF, Lubeck DP, et al. Longitudinal differences in disease specific quality of life in men with erectile dysfunction: Results from the exploratory comprehensive evaluation of erectile dysfunction study. Br J Urol. 2003;169(4):1437-1442.
Laumann Edward O, West Suzanne, Glasser Dale, et al. Prevalence and Correlates of Erectile Dysfunction by Race and Ethnicity Among Men Aged 40 or Older in the United States: From the Male Attitudes Regarding Sexual Health Survey. [References]. Br J Sex Med. 2007;4(1):57-65.
Lawless C, Cree J. Oral medications in the management of erectile dysfunction. [Review] [15 refs]. J Am Board Fam Pract. 1998;11(4):307-314. [pmid: 9719353].
Lawless C, Force RW. Sildenafil for erectile dysfunction. J Fam Pract. 1998;47(2):97-98. [pmid: 9722794].
Lawrence IG, Price DE, Howlett TA, et al. Correcting impotence in the male dialysis patient: experience with testosterone replacement and vacuum tumescence therapy. Am J Kidney Dis. 1998;31(2):313-319. [pmid: 9469503].
Lea AP, Bryson HM, Balfour JA. Intracavernous alprostadil. A review of its pharmacodynamic and pharmacokinetic properties and therapeutic potential in erectile dysfunction. [Review] [123 refs]. Drugs Aging. 1996;8(1):56-74. [pmid: 8785470].
Lebret T, Herve JM, Gorny P, et al. Efficacy and safety of a novel combination of L-arginine glutamate and yohimbine hydrochloride: a new oral therapy for erectile dysfunction. Eur Urol. 2002;41(6):608-613. [pmid: 12074777].
Lee W R. The role of androgen deprivation therapy combined with prostate brachytherapy. [Review][31 refs]. Urology 2002;60(3:Suppl 1):Suppl-44.
Lehmann K, Casella R, Blochlinger A, et al. Reasons for discontinuing intracavernous injection therapy with prostaglandin E1 (alprostadil). Urology. 1999;53(2):397-400. [pmid: 9933062].
Lehmann K, John H, Kacl G, et al. Variable response to intracavernous prostaglandin E1 testing for erectile dysfunction. Urology. 1999;54(3):539-543. [pmid: 10475368].
Lenze EJ, Karp JF, Mulsant BH, et al. Somatic symptoms in late-life anxiety: Treatment issues. Journal of Geriatric Psychiatry & Neurology. 2005;18(2):89-96. [pmid: 15911937].
Lenzi A. The role of the medical andrologist in the assisted reproduction era. J Endocrinol Invest. 2003;26(3):268-273. [pmid: 12809180].
Leslie SJ, Atkins G, Oliver JJ, et al. No adverse hemodynamic interaction between sildenafil and red wine. Clinical Pharmacology & Therapeutics. 2004;76(4):365-370. [pmid: 15470336].
Levien T, Baker DE. Lepirudin and sildenafil citrate. Hosp Pharm. 1998;33(12):1524-1552.
Levine SB. A slightly different idea. Arch Sex Behav. 2005;34(1):38-39. [pmid: 16092025].
Levy MM. Benefits being missed [5]. Can Pharm J. 2005;274(7334):109.
Lewis RL, Sadovsky R, Eardley I, et al. The efficacy of tadalafil in clinical populations. Br J Sex Med. 2005;2(4):517-531.
Lexchin J. New drugs with novel therapeutic characteristics. Have they been subject to randomized controlled trials?. Can Fam Physician. 2002;48(SEPT.):1487-1492. [pmid: 12371307].
Li JY, Li XY, Li M, et al. Decline of serum levels of free testosterone in aging healthy Chinese men. Aging Male. 2005;8(34):203-206. [pmid: 16390747].
Licht MR. Use of oral sildenafil (Viagra) in the treatment of erectile dysfunction. [Review] [13 refs]. Compr Ther. 1999;25(2):90-94. [pmid: 10091013].
Lim PHC, Man KL, Foo CN, et al. Clinical efficacy and safety of sildenafil citrate (Viagra) in a multi-racial population in Singapore: A retrospective study of 1520 patients. Int J Urol. 2002;9(6):308-315. [pmid: 12110094].
Lim P H C, Moorthy P, Benton K G F. The clinical safety of Viagra. Ann N Y Acad Sci 2002;962(pp 378–388):-388.
Limoge JP, Olins E, Henderson D, et al. Minimally invasive therapies in the treatment of erectile dysfunction in anticoagulated cases: a study of satisfaction and safety. Br J Urol. 1996;155(4):1276-1279.
Lin CS, Xin ZC, Lin G, et al. Phosphodiesterases as therapeutic targets. Urology. 2003;61(4):685-691. [pmid: 12670544].
Lincoln TM. Cyclic GMP and phosphodiesterase 5 inhibitor therapies: What's on the horizon. Mol Pharmacol. 2004;66(1):11-13. [pmid: 15213291].
Lindsey I. What is the incidence of sexual dysfunction in males following rectal excision for benign and malignant diseases?. National Research Register 2000;2000.
Linet OI, Neff LL. Intracavernous prostaglandin E1 in erectile dysfunction. Clin Investig. 1994;72(2):139-149.
Linnebur SA. Pharmacotherapy update: What's new about old medications. Annals of Long Term Care. 2004;12(9):34-44.
Lipshultz LI. Injection therapy for erectile dysfunction. N Engl J Med. 1996;334(14):913-914. [pmid: 8596577].
Lipshultz LI, Kim ED. Treatment of erectile dysfunction in men with diabetes. J Am Med Assoc. 1999;281(5):465-466.
Llisterri JL, Lozano Vidal JV, Aznar Vicente J, et al. Sexual dysfunction in hypertensive patients treated with losartan. Am J Med Sci. 2001;321(5):336-341. [pmid: 11370797].
Long RL, Sherman LS, Lombardi TJ. A goal-oriented, cost-effective approach to the diagnosis and treatment of 24 male erectile dysfunction. [Review] [24 refs]. J Ky Med Assoc. 1995;93(11):500-508. [pmid: 8778212].
Loudon Julia B. Potential confusion between erectile dysfunction and premature ejaculation: An evaluation of men presenting with erectile difficulty at a sex therapy clinic. Sexual & Marital Therapy. 1998;13(4):397-403.
Lu J, SJ Fan J, Zhu J, et al. The prospective and randomized control study of Viagra combined with Andriol in the treatment of ED in the aging male. Chinese Journal of Andrology. 2003;17(3):194-196.
Lue TF. Erectile dysfunction. N Engl J Med. 2000;342(24):1802-1813. [pmid: 10853004].
Lue TF. Impotence after radical pelvic surgery: physiology and management. [Review] [56 refs]. Urol Int. 1991;46(3):259-265. [pmid: 1926639].
Lukkarinen O, Tonttila P, Hellstrom P, et al. Non-prosthetic surgery in the treatment of erectile dysfunction. A retrospective study of 45 impotent patients in the University of Oulu. Scandinavian Journal of Urology & Nephrology. 1998;32(1):42-46. [pmid: 9561573].
Lunenfeld B. Androgen therapy in the aging male. [Review] [110 refs]. World J Urol. 2003;21(5):292-305. [pmid: 14576959].
Maan Z, Arya M, Shergill I, et al. Peyronie's disease: An update of the medical management. Expert Opin Pharmacother. 2004;5(4):799-805. [pmid: 15102564].
Maas R, Schwedhelm E, Albsmeier J, et al. The pathophysiology of erectile dysfunction related to endothelial dysfunction and mediators of vascular function. Vasc Med. 2002;7(3):213-225. [pmid: 12553745].
Mahmud A, Hennessy M, Feely J. Effect of sildenafil on blood pressure and arterial wave reflection in treated hypertensive men. J Hum Hypertens. 2001;15(10):707-713. [pmid: 11607801].
Maier U, Koinig G. Andrological findings in young patients under long-term antidepressive therapy with clomipramine. Psychopharmacology (Berl). 1994;116(3):357-359. [pmid: 7892427].
Mak R, De Backer G, Kornitzer M, et al. Prevalence and correlates of erectile dysfunction in a population-based study in Belgium. Eur Urol. 2002;41(2):132-138. [pmid: 12074399].
Manasia P, Pomerol J, Ribe N, et al. Comparison of the efficacy and safety of 90 mg versus 20 mg fluoxetine in the treatment of premature ejaculation. Br J Urol. 2003;170(1):164-165.
Manecke RG, Mulhall JP. Medical treatment of erectile dysfunction. [Review] [69 refs]. Ann Med. 1999;31(6):388-398. [pmid: 10680853].
Manganiello V. International Journal of Impotence Research: Editorial commentary. Int J Impot Res. 2004;16(SUPPL. 1):S1-S3. [pmid: 15224126].
Mann K, Klingler T, Noe S, et al. Effects of yohimbine on sexual experiences and nocturnal penile tumescence and rigidity in erectile dysfunction. Arch Sex Behav. 1996;25(1):1-16. [pmid: 8714425].
Mann RD. Introduction - Tadalafil. Journal of Drug Evaluation. 2004;2(8):223.
Mann RD. Executive summary sildenafil citrate (Viagra). Journal of Drug Evaluation. 2003;1(7):221-223.
Manning M, Junemann KP, Scheepe JR, et al. Long-term followup and selection criteria for penile revascularization in erectile failure.[see comment]. Br J Urol. 1998;160(5):1680-1684.
Marberger M, Roehrborn CG, Marks LS, et al. Relationship among serum testosterone, sexual function, and response to treatment in men receiving dutasteride for benign prostatic hyperplasia. Journal of Clinical Endocrinology & Metabolism. 2006;91(4):1323-1328. [pmid: 16434455].
Margel D, Tal R, Livne PM, et al. Predictors of erectile function improvement in obstructive sleep apnea patients with long-term CPAP treatment. Int J Impot Res. 2005;17(2):186-190. [pmid: 15510189].
Mark SD, Keane TE, Vandemark RM, et al. Impotence following pelvic fracture urethral injury: incidence, aetiology and management. Br J Urol. 1995;75(1):62-64. [pmid: 7850299].
Markou S, Perimenis P, Gyftopoulos K, et al. Vardenafil (Levitra) for erectile dysfunction: a systematic review and meta-analysis of clinical trial reports. Int J Impot Res. 2004;16(6):470-478. [pmid: 15229625].
Marquer C, Bressolle F. Moxisylyte: A review of its pharmacodynamic and pharmacokinetic properties, and its therapeutic use in impotence. Fundam Clin Pharmacol. 1998;12(4):377-387. [pmid: 9711459].
Martin DJ, Badwan K, Parker M, et al. Transdermal application of verapamil gel to the penile shaft fails to infiltrate the tunica albuginea. Br J Urol. 2002;168(6):2483-2485.
Martins FE, Reis JP. Visual erotic stimulation test for initial screening of psychogenic erectile dysfunction: a reliable noninvasive alternative?. Br J Urol. 1997;157(1):134-139.
Masand PS, Ashton AK, Gupta S, et al. Sustained-release bupropion for selective serotonin reuptake inhibitor-induced sexual dysfunction: a randomized, double-blind, placebo-controlled, parallel-group study.[see comment]. Am J Psychiatry. 2001;158(5):805-807. [pmid: 11329407].
Matthew AG, Goldman A, Trachtenberg J, et al. Sexual dysfunction after radical prostatectomy: Prevalence, treatments, restricted use of treatments and distress. Br J Urol. 2005;174(6):2105-2110.
Maytom MC, Derry FA, Dinsmore WW, et al. A two-part pilot study of sildenafil (VIAGRA) in men with erectile dysfunction caused by spinal cord injury. Spinal Cord. 1999;37(2):110-116. [pmid: 10065749].
McCarthy Barry W. Relapse prevention strategies and techniques with erectile dysfunction. J Sex Marital Ther. 2001;27(1):1-8. [pmid: 11224950].
McClellan KJ, Goa KL. Transdermal testosterone. [Review] [17 refs]. Drugs. 1998;55(2):253-258. [pmid: 9506244].
McClure RD. Endocrine evaluation and therapy of erectile dysfunction. [Review] [77 refs]. Urol Clin North Am. 1988;15(1):53-64. [pmid: 3278476].
McConnell JD, Roehrborn CG, Bautista OM, et al. The Long-Term Effect of Doxazosin, Finasteride, and Combination Therapy on the Clinical Progression of Benign Prostatic Hyperplasia. N Engl J Med. 2003;349(25):2387-2398. [pmid: 14681504].
McCullough AR, Barada JH, Fawzy A, et al. Achieving treatment optimization with sildenafil citrate (Viagra) in patients with erectile dysfunction. Urology. 2002;60(2 Suppl 2):28-38. [pmid: 12414331].
McKinlay J B. The worldwide prevalence and epidemiology of erectile dysfunction. [Review][17 refs]. Int J Impot Res 2000;12Suppl-S11.
McMahon C. Comparison of erectile responses to differing doses of prostaglandin PGE1 in an attempt to standardise pharmacological diagnosis of impotence. Journal of Assisted Reproduction & Genetics 1992;9265A
McMahon CG. Nonsurgical treatment of cavernosal venous leakage. Urology. 1997;49(1):97-100. [pmid: 9000193].
McMahon CG. Treatment of Erectile Dysfunction with Chronic Dosing of Tadalafil. Eur Urol. 2006;50(2):215-217. [pmid: 16844542].
McMahon CG. Priapism associated with concurrent use of phosphodiesterase inhibitor drugs and intracavernous injection therapy. Int J Impot Res. 2003;15(5):383-384. [pmid: 14562142].
McMahon CG, Stuckey BGA, Andersen M, et al. Efficacy of sildenafil citrate (viagra) in men with premature ejaculation. Br J Sex Med. 2005;2(3):368-375.
Mealy NE. NBI-69733. Drugs of the Future. 2004;29(6):642.
Mealy NE. GPI-1485. Drugs of the Future. 2004;29(6):640.
Mealy NE. EMR-62203. Drugs of the Future. 2004;29(6):639.
Mealy NE. Dasantafil. Drugs of the Future. 2004;29(6):633.
Mealy NE. DA-8159. Drugs of the Future. 2004;29(6):631.
Mealy NE. Avanafil. Drugs of the Future. 2004;29(6):628-629.
Mealy NE. Alprostadil cream. Drugs of the Future. 2004;29(6):626-627.
Mealy NE, Bayes M. PT-141. Drugs of the Future. 2004;29(11):1177.
Mealy NE, Bayes M. ABT-724. Drugs of the Future. 2005;30(9):935.
Mehdiyev T V. Intracavernous injection probe of vasoactive preparations in the diagnosis of erectile dysfunctions in patients with diabetes mellitus. Azerbaidzhanskii Meditsinskii Zhurnal 2002;(pp 17–19):-19.
Meinhardt W, Kropman RF, Vermeij P, et al. The influence of medication on erectile function. Int J Impot Res. 1997;9(1):17-26. [pmid: 9138055].
Melman A, Bar-Chama N, McCullough A, et al. The first human trial for gene transfer therapy for the treatment of erectile dysfunction: preliminary results. Eur Urol. 2005;48(2):314-318. [pmid: 15964135].
Mendelson WB, Gujavarty K, Slintak C, et al. Reported sexual dysfunction in obstructive sleep apnea patients. Ann Clin Psychiatry. 1990;2(2):93-101.
Merrick GS, Wallner KE, Butler WM. Minimizing prostate brachytherapy-related morbidity. Urology. 2003;62(5):786-792. [pmid: 14624895].
Metawea B, El-Nashar AR, Gad-Allah A, et al. Intracavernous papaverine/phentolamine-induced priapism can be accurately predicted with color Doppler ultrasonography. Urology. 2005;66(4):858-860. [pmid: 16230153].
Meyhoff HH, Rosenkilde P, Bodker A. Non-invasive management of impotence with transcutaneous nitroglycerin. Br J Urol. 1992;69(1):88-90. [pmid: 1737261].
Migliari R, Muscas G, Usai E. Effect of Casodex on sleep-related erections in patients with advanced prostate cancer. Br J Urol. 1992;148(2 I):338-341.
Mikhail N. Efficacy and safety of sildenafil in patients with congestive heart failure [7]. Arch Intern Med. 2004;164(18):2067-2068. [pmid: 15477449].
Millard RJ, Stricker PD, Lynch WJ, et al. Risks of self-injection therapy for impotence. Med J Aust. 1996;165(2):117-118. [pmid: 8692055].
Miller DC, Wei JT, Dunn RL, et al. Use of medications or devices for erectile dysfunction among long-term prostate cancer treatment survivors: potential influence of sexual motivation and/or indifference. Urology. 2006;68(1):166-171. [pmid: 16844457].
Miller N, Smolkin ME, Bissonette E, et al. Undetectable prostate specific antigen at 6–12 months: a new marker for early success in hormonally treated patients after prostate brachytherapy. Cancer. 2005;103(12):2499-2506. [pmid: 15852361].
Mills RD, Sethia KK. Maximisation of the erectile response in the investigation of impotence. Int J Impot Res. 1999;11(1):29-32. [pmid: 10098951].
Mills TM, Lewis RW. The role of androgens in the erectile response: A 1999 perspective. Mol Urol. 1999;3(2):75-80. [pmid: 10851308].
Milman HA, Arnold SB, Rivera-Miranda G, et al. Neurologic, psychological, and aggressive disturbances with sildenafil. Ann Pharmacother. 2002;36(78):1129-1134. [pmid: 12086542].
Mirone VG, Stief CG. Efficacy of apomorphine SL in erectile dysfunction.[erratum appears in BJU Int 2002 Jan;89(1):140]. [Review] [11 refs]. BJU Int. 2001;88(Suppl 3):25-29. [pmid: 11578276].
Mittleman MA, Glasser DB, Orazem J. Clinical trials of sildenafil citrate (Viagra) demonstrate no increase in risk of myocardial infarction and cardiovascular death compared with placebo. Int J Clin Pract. 2003;57(7):597-600. [pmid: 14529061].
Mittleman MM, Rosen RC. Evaluating clinical trial design results and analysis of drug treatments for erectile dysfunction. Int J Impot Res. 2003;15(4):x-xiii.
Miwa Y, Kaneda T, Yokoyama O. Correlation between the Aging Males' Symptoms Scale and sex steroids, gonadotropins, dehydroepiandrosterone sulfate, and growth hormone levels in ambulatory men. Br J Sex Med. 2006;3(4):723-726.
Mohr BA, Bhasin S, Link CL, et al. The effect of changes in adiposity on testosterone levels in older men: longitudinal results from the Massachusetts Male Aging Study. Eur J Endocrinol. 2006;155(3):443-452. [pmid: 16914599].
Montejo A L, Llorca G, Izquierdo J A et al. Incidence of sexual dysfunction associated with antidepressant agents: a prospective multicenter study of 1022 outpatients. Spanish Working Group for the Study of Psychotropic-Related Sexual Dysfunction.[see comment]. Hillside J Clin Psychiatry 2001;62Suppl-21.
Montejo-Gonzalez AL, Llorca G, Izquierdo JA, et al. SSRI-induced sexual dysfunction: fluoxetine, paroxetine, sertraline, and fluvoxamine in a prospective, multicenter, and descriptive clinical study of 344 patients. Journal of Sex and Marital Therapy. 1997;23(3):176-194. [pmid: 9292833].
Montorsi F. A multicenter, randomized, double-blind, crossover study to evaluate patient preference between tadalafil and sildenafil: Editorial comment. Eur Urol. 2004;45(4):508-509.
Montorsi F, Althof SE. Partner responses to sildenafil citrate (Viagra) treatment of erectile dysfunction. Urology. 2004;63(4):762-767. [pmid: 15072897].
Montorsi F, Burnett AL. Erectile dysfunction after radical prostatectomy. BJU Int. 2004;93(1):1-2. [pmid: 14678354].
Montorsi F, Briganti A, Salonia A, et al. Current and Future Strategies for Preventing and Managing Erectile Dysfunction Following Radical Prostatectomy. Eur Urol. 2004;45(2):123-133. [pmid: 14733995].
Montorsi F, Briganti A, Salonia A, et al. Can Phosphodiesterase Type 5 Inhibitors Cure Erectile Dysfunction?. Eur Urol. 2006;49(6):979-986. [pmid: 16431013].
Montorsi F, Guazzoni G, Bocciardi A, et al. Improved minimally-invasive assessment of penile haemodynamics: the combination of colour Doppler sonography and injection-stimulation test. Int J Impot Res. 1995;7(1):33-40. [pmid: 7670591].
Montorsi F, Perani D, Anchisi D, et al. Brain activation patterns during video sexual stimulation following the administration of apomorphine: results of a placebo-controlled study. Eur Urol. 2003;43(4):405-411. [pmid: 12667722].
Montorsi F, Salonia A, Briganti A, et al. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol. 2005;47(5):612-621. [pmid: 15826752].
Montorsi F, Strambi LF, Guazzoni G, et al. Effect of yohimbine-trazodone on psychogenic impotence: a randomized, double-blind, placebo-controlled study. Urology. 1994;44(5):732-736. [pmid: 7974947].
Moore R A, Edwards J E, McQuay H J. Sildenafil (Viagra) for male erectile dysfunction: a meta-analysis of clinical trial reports. BMC Urol. 2002;26
Morales A. Men's aging and sexual disorders: An update on diagnosis and treatment. Rev Endocr Metab Disord. 2005;6(2):85-92. [pmid: 15843879].
Morales A, Gingell C, Collins M, et al. Clinical safety of oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):69-73. [pmid: 9647940].
Morales Alvaro, Condra Michael, Heaton Jeremy P, et al. Impotence: Organic factors and management approach. Sexual & Marital Therapy. 1991;6(2):97-106.
Moreira ED, Lbo CF, Diament A, et al. Incidence of erectile dysfunction in men 40 to 69 years old: results from a population-based cohort study in Brazil. Urology. 2003;61(2):431-436. [pmid: 12597962].
Moreira E D, Lisboa Lobo C F, Villa M et al. Prevalence and correlates of erectile dysfunction in Salvador, northeastern Brazil: a population-based study. Int J Impot Res 2002;14Suppl-9.
Morley John E, Kaiser Fran E. Aging and sexuality. Vellas, Bruno (Ed); Albarede, J 1992;-L(Ed):1992-165.
Mulhall JP. Deciphering erectile dysfunction drug trials. [Review] [35 refs]. Br J Urol. 2003;170(2 Pt 1):353-358.
Mulhall JP. Sublingual apomorphine for the treatment of erectile dysfunction. [Review] [22 refs]. Expert Opin Investig Drugs. 2002;11(2):295-302.
Mulhall JP, bdel-Moneim A, Abobakr R, et al. Improving the accuracy of vascular testing in impotent men: correcting hemodynamic alterations using a vasoactive medication re-dosing schedule. Br J Urol. 2001;166(3):923-926.
Mulhall JP, Daller M, Traish AM, et al. Intracavernosal forskolin: Role in management of vasculogenic impotence resistant to standard 3-agent pharmacotherapy. Br J Urol. 1997;158(5):1752-1759.
Mulhall JP, Levine LA, Junemann KP. Erection hardness: a unifying factor for defining response in the treatment of erectile dysfunction. [Review] [37 refs]. Urology. 2006;68(3 Suppl):17-25. [pmid: 17011372].
Mulligan T, Schmitt B. Testosterone for erectile failure. J Gen Intern Med. 1993;8(9):517-521. [pmid: 8410427].
Mulligan T, Frick MF, Zuraw QC, et al. Prevalence of hypogonadism in males aged at least 45 years: the HIM study. Int J Clin Pract. 2006;60(7):762-769. [pmid: 16846397].
Muneer A, Ralph DJ, Minhas S. Sildenafil citrate (Viagra). Journal of Drug Evaluation. 2003;1(7):225-246.
Munoz M, Bancroft J, Beard M. Evaluating the effects of an alpha-2 adrenoceptor antagonist on erectile function in the human male. 2. The erectile response to erotic stimuli in men with erectile dysfunction, in relation to age and in comparison with normal volunteers. Psychopharmacology (Berl). 1994;115(4):471-477. [pmid: 7871091].
Munoz M, Bancroft J, Turner M. Evaluating the effects of an alpha-2 adrenoceptor antagonist on erectile function in the human male. 1. The erectile response to erotic stimuli in volunteers. Psychopharmacology (Berl). 1994;115(4):463-470. [pmid: 7871090].
Murphy AM, O'Leary M. Failure of the Ambicor inflatable penile prosthesis to deflate. Int J Impot Res. 2005;17(3):291-292. [pmid: 15605073].
Murphy JC, Srinivas S, Terris MK. Flutamide administration at 500 mg daily has similar effects on serum testosterone to 750 mg daily. J Androl. 2004;25(4):630-634. [pmid: 15223852].
Nagai A, Kusumi N, Tsuboi H, et al. Intracavernous injection of prostaglandin E1 is effective in patients with erectile dysfunction not responding to phosphodiseterase 5 inhibitors. Acta Med Okayama. 2005;59(6):279-280. [pmid: 16418771].
Nakata M, Takashima S, Kaminou T, et al. Embolotherapy for venous impotence: use of ethanol. Journal of Vascular & Interventional Radiology. 2000;11(8):1053-1057. [pmid: 10997470].
Nakonezny PA, Byerly MJ, Rush AJ. The relationship between serum prolactin level and sexual functioning among male outpatients with schizophrenia or schizoaffective disorder: A randomized double-blind trial of risperidone vs. quetiapine. J Sex Marital Ther. 2007;33(3):203-216. [pmid: 17454518].
Nalesnik JG, Jones L, Kraus SR. Group B streptococcal septicemia following intracavernous injection therapy for erectile dysfunction in diabetes. Br J Urol. 2004;172(1):151-152.
Nandwani R, Gourlay Y. Possible interaction between sildenafil and HIV combination therapy [1]. Lancet. 1999;353(9155):840. [pmid: 10459981].
Narayan P, Trachtenberg J, Lepor H, et al. A dose-response study of the effect of flutamide on benign prostatic hyperplasia: results of a multicenter study. Urology. 1996;47(4):497-504. [pmid: 8638357].
Neese Leah E, Schover Leslie R, Klein Eric A, et al. Finding help for sexual problems after prostate cancer treatment: A phone survey of men's and women's perspectives. [References]. Psychooncology. 2003;12(5):463-473. [pmid: 12833559].
Nehra A, Blute ML, Barrett DM, et al. Rationale for combination therapy of intraurethral prostaglandin E(1) and sildenafil in the salvage of erectile dysfunction patients desiring noninvasive therapy. Int J Impot Res. 2002;14(Suppl 1):38-42. [pmid: 11896476].
Neumeyer K, Kirkpatrick P. Tadalafil and vardenafil. Nat Rev Genet. 2004;3(4):295-296.
Nicolosi A, Moreira ED, Shirai M, et al. Epidemiology of erectile dysfunction in four countries: cross-national study of the prevalence and correlates of erectile dysfunction. Urology. 2003;61(1):201-206. [pmid: 12559296].
Nieschlag E, Swerdloff R, Behre HM, et al. Investigation, treatment and monitoring of late-onset hypogonadism in males: ISA, ISSAM, and EAU recommendations. Int J Androl. 2005;28(3):125-127. [pmid: 15910536].
Nurnberg H G, Hensley P L. Sildenafil citrate for the management of antidepressant-associated erectile dysfunction. Hillside J Clin Psychiatry 2003;64Suppl-5.
Nurnberg HG, Gelenberg A, Hargreave TB, et al. Efficacy of sildenafil citrate for the treatment of erectile dysfunction in men taking serotonin reuptake inhibitors. Am J Psychiatry. 2001;158(11):1926-1928. [pmid: 11691705].
Nurnberg HG, Seidman SN, Gelenberg AJ, et al. Depression, antidepressant therapies, and erectile dysfunction: clinical trials of sildenafil citrate (Viagra) in treated and untreated patients with depression. Urology. 2002;60(2 Suppl 2):58-66. [pmid: 12414334].
Nurnberg H, George. Erectile Dysfunction and Comorbid Depression: Prevalence, Treatment Strategies, and Associated Medical Conditions. [References]. Hillside J Clin Psychiatry. 2003;64(Suppl10):3-4.
Nurnberg H, George Hensley, Paula L, et al. Sildenafil in the treatment of sexual dysfunction induced by selective serotonin reuptake inhibitors: An overview. [References]. CNS Drugs. 2000;13(5):321-335.
O'Sullivan JD. Apomorphine as an alternative to sildenafil in Parkinson's disease. [References]. Journal of Neurology, Neurosurgery & Psychiatry. 2002;72(5):681.
O'Sullivan JD, Hughes AJ. Apomorphine-induced penile erections in Parkinson's disease. Mov Disord. 1998;13(3):536-539. [pmid: 9613749].
Oefelein MG. Time to normalization of serum testosterone after 3-month luteinizing hormone-releasing hormone agonist administered in the neoadjuvant setting: implications for dosing schedule and neoadjuvant study consideration.[see comment]. Br J Urol. 1998;160(5):1685-1688.
Ohebshalom M, Mulhall JP. Transdermal and topical pharmacotherapy for male sexual dysfunction. Expert Opinion on Drug Delivery. 2005;2(1):115-120. [pmid: 16296739].
Ojumu A, Dobs AS. Is Hypogonadism a Risk Factor for Sexual Dysfunction?. J Androl. 2003;24(6 SUPPL.):S46-S51. [pmid: 14581495].
Onu PE. Depot medroxyprogesterone in the management of benign prostatic hyperplasia. Eur Urol. 1995;28(3):229-235. [pmid: 8536777].
Opsomer RJ, Wese FX, De Groote P, et al. The external vacuum device in the management of erectile dysfunction. Acta Urol Belg. 1997;65(4):13-16. [pmid: 9497591].
Ormrod D, Easthope SE, Figgitt DP. Vardenafil.[erratum appears in Drugs Aging 2002;19(11):886]. [Review] [30 refs]. Drugs Aging. 2002;19(3):217-227. [pmid: 12027779].
Osterloh IH, Riley A. Clinical update on sildenafil citrate. [Review] [58 refs]. Br J Clin Pharmacol. 2002;53(3):219-223. [pmid: 11874383].
Osterloh I H, Collins M, Wicker P et al. Sildenafil citrate (VIAGRA): overall safety profile in 18 doubleblind, placebo controlled, clinical trials. [Review][0 refs]. Int J Clin Pract 1999;Supplement.102–105.
Owens J. Seeking selectivity. Nat Rev Genet. 2005;4(2):106.
Ozbek E, Yurekli M, Soylu A, et al. The role of adrenomedullin in varicocele and impotence. BJU Int. 2000;86(6):694-698. [pmid: 11069379].
Ozdel O, Oguzhanoglu A, Oguzhanoglu NK, et al. A follow-up study of male sexual disorders: The neurophysiological assessments, anxiety-depression levels, and response to fluoxetine treatment [10]. J Clin Psychopharmacol. 2004;24(4):461-463. [pmid: 15232347].
Padma-Nathan H, Eardley I, Kloner R A et al. A 4-year update on the safety of sildenafil citrate (Viagra). [Review][88 refs]. Urology 2002;60(2:Suppl 2):Suppl-90.
Pagani E, Glina S, Puech-Leao P, et al. Anxiety and high plasma catecholamines do not impair pharmaco-induced erection of psychogenic erectile dysfunctional patients. Int J Impot Res. 2003;15(4):282-286. [pmid: 12934057].
Paice Judith A, Penn Richard D, Ryan Will G. Altered sexual function and decreased testosterone in patients receiving intraspinal opioids. J Pain Symptom Manage. 1994;9(2):126-131. [pmid: 7517429].
Paick JS, Yang JH, Kim SW, et al. Severity of erectile dysfunction in married impotent patients: interrelationship with anthropometry, hormones, metabolic profiles and lifestyle. Int J Urol. 2007;14(1):48-53. [pmid: 17199860].
Paick JS, Yang JH, Kim SW, et al. The role of prolactin levels in the sexual activity of married men with erectile dysfunction. BJU Int. 2006;98(6):1269-1273. [pmid: 17125484].
Paick SH, Meehan A, Lee M, et al. The relationship among lower urinary tract symptoms, prostate specific antigen and erectile dysfunction in men with benign prostatic hyperplasia: results from the proscar long-term efficacy and safety study. Br J Urol. 2005;173(3):903-907.
Palha AP, Gomes FA, Martins AS, et al. [Clinical, multicentric, and open study to evaluate the efficacy of and tolerance to sildenafil in patients with erectile dysfunction]. Acta Med Port. 2002;15(4):249-256. [pmid: 12525018].
Pan CC, Lin JSN, Wong WS. Comparison of effect on erection between vacuum constriction devices and intra-cavernous injection of prostaglandin E1. Asian J Surg. 1997;20(2):162-166.
Papatsoris AG, Deliveliotis C, Singer C, et al. Erectile dysfunction in Parkinson's disease. Urology. 2006;67(3):447-451. [pmid: 16504269].
Parazzini F, Menchini Fabris F, Bortolotti A, et al. Frequency and determinants of erectile dysfunction in Italy. Eur Urol. 2000;37(1):43-49. [pmid: 10671784].
Paris G, Sponsel WE, Sandoval SS, et al. Sildenafil increases ocular perfusion. Int Ophthalmol. 2001;23(46):355-358. [pmid: 11944862].
Parker C. The Scandinavian Prostate Cancer Group Study: The case for conservative management. BJU Int. 2005;96(7):952-953. [pmid: 16225505].
Parsons JK, Marschke P, Maples P, et al. Effect of methylprednisolone on return of sexual function after nerve-sparing radical retropubic prostatectomy. Urology. 2004;64(5):987-990. [pmid: 15533491].
Patankar M. Sildenafil citrate. J Indian Med Assoc 2000;98(12):
Patterson D, Kloner R, Effron M, et al. The effect of tadalafil on the time to exercise-induced myocardial ischaemia in subjects with coronary artery disease. Br J Clin Pharmacol. 2005;60(5):459-468. [pmid: 16236035].
Pegge NC, Twomey AM, Vaughton K, et al. The role of endothelial dysfunction in the pathophysiology of erectile dysfunction in diabetes and in determining response to treatment. Diabet Med. 2006;23(8):873-878. [pmid: 16911625].
Penninga E, Jensen BA, Hansen PB, et al. Anagrelide treatment in 52 patients with chronic myeloproliferative diseases. Clinical & Laboratory Haematology. 2004;26(5):335-340. [pmid: 15485463].
Penson DF, Feng Z, Kuniyuki A, et al. General quality of life 2 years following treatment for prostate cancer: what influences outcomes? Results from the prostate cancer outcomes study.[see comment]. Am J Clin Oncol. 2003;21(6):1147-1154.
Perez Martin A, Skinner Eila C, Meyerowitz Beth EE. Sexuality and intimacy following radical prostatectomy: Patient and partner perspectives. [References]. Health Psychol. 2002;21(3):288-293. [pmid: 12027035].
Perimenis P, Athanasopoulos A, Papathanasopoulos P, et al. Gabapentin in the management of the recurrent, refractory, idiopathic priapism. Int J Impot Res. 2004;16(1):84-85. [pmid: 14963477].
Pescatori ES, Calpista A, Artibani W, et al. Self-injection devices for intracavernosal pharmacotherapy: operational classification and safety considerations. Int J Impot Res. 1996;8(2):53-57. [pmid: 8858390].
Pescatori ES, Silingardi V, Galeazzi GM, et al. Audiovisual sexual stimulation by virtual glasses is effective in inducing complete cavernosal smooth muscle relaxation: a pharmacocavernosometric study. Int J Impot Res. 2000;12(2):83-88. [pmid: 11052633].
Phelps JS, Jain A, Monga M. The PsychoedPlusMed approach to erectile dysfunction treatment: the impact of combining a psychoeducational intervention with sildenafil. J Sex Marital Ther. 2004;30(5):305-314. [pmid: 15672598].
Philipp M, Kohnen R, Benkert O. A comparison study of moclobemide and doxepin in major depression with special reference to effects on sexual dysfunction. Int Clin Psychopharmacol. 1993;7(34):149-153. [pmid: 8468436].
Philipp M, Tiller JWG, Baier D, et al. Comparison of moclobemide with selective serotonin reuptake inhibitors (SSRIs) on sexual function in depressed adults. Eur Neuropsychopharmacol. 2000;10(5):305-314. [pmid: 10974600].
Phillips BG, Kato M, Pesek CA, et al. Sympathetic activation by sildenafil.[see comment]. Circulation. 2000;102(25):3068-3073. [pmid: 11120696].
Pirotte B, de Tullio P, Antoine MH, et al. New insights into the development of ATP-sensitive potassium channel openers. Expert Opinion on Therapeutic Patents. 2005;15(5):497-504.
Pisters LL, von Eschenbach AC, Scott SM, et al. The efficacy and complications of salvage cryotherapy of the prostate. J Urol. 1997;157(3):921-925. [pmid: 9072600].
Pittler M, Ernst E. Trials have shown yohimbine is effective for erectile dysfunction [14]. Br Med J. 1998;317(7156):478. [pmid: 9703549].
Polak K, Wimpissinger B, Berisha F, et al. Effects of sildenafil on retinal blood flow and flicker-induced retinal vasodilatation in healthy subjects. Invest Ophthalmol Vis Sci. 2003;44(11):4872-4876. [pmid: 14578411].
Pollack Mark H, Reiter Stewart, Hammerness Paul. Genitourinary and sexual adverse effects of psychotropic medication. Int J Psychiatry Med. 1992;22(4):305-327. [pmid: 1363418].
Pomara G, Morelli G, Montorsi F, et al. Re: Montorsi F, Salonia A, Briganti A, Barbieri L, Zanni G, Surdi N, Cestari A, Montorsi P, Rigatti P. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol 2005;47:612–21 (multiple letters). Eur Urol. 2005;48(2):345-346. [pmid: 15939526].
Pomerantz JM. Viagra and medical necessity. Drug Benefit Trends. 2002;14(10):33-40.
Pommerville P. Drug treatments for erectile dysfunction: An update. Geriatrics and Aging. 2004;7(6):10-16.
Pommerville P J. From bedside to bed. Recovery of sexual function after prostate cancer. Can Fam Physician 2005;51(JULY):941–-943+948.
Porst H. IC351 (tadalafil, Cialis): update on clinical experience. [Review][12 refs]. Int J Impot Res 2002;14Suppl-64.
Porst H. Phosphodiesterase type-5 inhibitors: A critical comparative analysis. Eau Update Series. 2004;2(2):56-63.
Porst HC. Re-dosing of prostaglandin-E1 versus prostaglandin-E1 plus phentolamine in male erectile dysfunction: a dynamic color power Doppler study. Int J Impot Res. 2000;12(2):134-135. [pmid: 11052645].
Porst H, Giuliano F, Glina S, et al. Evaluation of the Efficacy and Safety of Once-a-Day Dosing of Tadalafil 5 mg and 10 mg in the Treatment of Erectile Dysfunction: Results of a Multicenter, Randomized, Double-Blind, Placebo-Controlled Trial. Eur Urol. 2006;50(2):351-359. [pmid: 16766116].
Pouaha J, Martin S, Reichert-Penetrat S, et al. Thalidomide and sexual dysfunction in men.[comment]. Br J Dermatol. 2002;146(6):1112-1113. [pmid: 12072099].
Power-Smith Parsley. Beneficial sexual side-effects from fluoxetine. Br J Psychiatry Suppl 1994;164 Feb 1994, 249–250. http249–250.
Pradeep C, Car N, Metelko Z. Impotence in diabetic men. Diabetol Croat. 1996;25(2):61-68.
Pratt-Ubunama MN, Nishizaka MK, Calhoun DA. Aldosterone antagonism: An emerging strategy for effective blood pressure lowering. Curr Hypertens Rep. 2005;7(3):186-192. [pmid: 15913492].
Preskorn SH. Duloxetine. Journal of Psychiatric Practice. 2004;10(6):375-385. [pmid: 15583519].
Price DE, Cooksey G, Jehu D, et al. The management of impotence in diabetic men by vacuum tumescence therapy. Diabet Med. 1991;8(10):964-967. [pmid: 1838050].
Prins J, Blanker MH, Bohnen AM, et al. Prevalence of erectile dysfunction: A systematic review of population-based studies. Int J Impot Res. 2002;14(6):422-432. [pmid: 12494273].
Priyadarshi S. Oral terbutaline in the management of pharmacologically induced prolonged erection. Int J Impot Res. 2004;16(5):424-426. [pmid: 14999218].
Pryor J. Vardenafil: update on clinical experience. [Review][10 refs]. Int J Impot Res 2002;14Suppl-9.
Pryor JP. Orgasmic and ejaculatory dysfunction. Sexual & Relationship Therapy. 2002;17(1):87-95.
Qian LX, Wu HF, Xu H, et al. Multi-center Evaluation of Efficacy and Safety of Oral Mesylate Phentolamine for the Treatment of Erectile Dysfunction. Int J Androl. 2001;7(5):302-305.
Quinn MJ, Jefferson K, Persad R. Benign prostatic hyperplasia and sexual dysfunction [3] (multiple letters). Lancet. 2003;361(9368):1562. [pmid: 12737897].
Quirk J, Thornton M, Neumeyer K, et al. Cardiology and vascular disorders. Nat Rev Genet. 2004;3(7 SUPPL.):S12-S17.
Radomski SB, Herschorn S, Rangaswamy S. Topical minoxidil in the treatment of male erectile dysfunction. Br J Urol. 1994;151(5):1225-1226.
Ramasubbu R. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Ramasubbu Rajamannar. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Ramasubbu Rajamannar. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Rashid A. The efficacy and safety of PDE5 inhibitors. [Review] [30 refs]. Clin Cornerstone. 2005;7(1):47-56. [pmid: 16156423].
Reffelmann T, Kloner RA. Effects of sildenafil on myocardial infarct size, microvascular function, and acute ischemic left ventricular dilation. Cardiovasc Res. 2003;59(2):441-449. [pmid: 12909327].
Reyes JA, Tan DA, Quimpo JA, et al. The Philippine Male Aging Survey. Aging Male. 2004;7(3):227-235. [pmid: 15669542].
Rhoden EL, Estrada C, Levine L, et al. The value of pituitary magnetic resonance imaging in men with hypogonadism.[see comment]. Br J Urol. 2003;170(3):795-798.
Richardson JD. Intracorporeal injections for the treatment of impotence. Med J Aust. 1991;155(10):688. [pmid: 1943899].
Richter S, Vardi Y, Ringel A, et al. Intracavernous injections: still the gold standard for treatment of erectile dysfunction in elderly men. Int J Impot Res. 2001;13(3):172-175. [pmid: 11525316].
Riley Alan. Oral treatments for erectile dysfunction. Int J STD AIDS. 1996;7(Suppl 3):16-18. [pmid: 8876375].
Rizvi K, Hampson JP, Harvey JN. Do lipid-lowering drugs cause erectile dysfunction? A systematic review.[see comment]. [Review] [35 refs]. Fam Pract. 2002;19(1):95-98. [pmid: 11818357].
Roach M, Winter K, Michalski JM, et al. Penile bulb dose and impotence after three-dimensional conformal radiotherapy for prostate cancer on RTOG 9406: findings from a prospective, multi-institutional, phase I/II dose-escalation study. Int J Radiat Oncol Biol Phys. 2004;60(5):1351-1356. [pmid: 15590164].
Rodrigues M, Granegger S, O'Grady J, et al. Accumulation of platelets as a key mechanism of human erection. A scintigraphic study in patients with erectile dysfunction receiving intracavernous injection of PGE1, papaverine/phentolamine. Advances in Experimental Medicine & Biology. 1997;43:379-82.
Roizenblatt S, Guilleminault C, Poyares D, et al. A double-blind, placebo-controlled, crossover study of sildenafil in obstructive sleep apnea. Arch Intern Med. 2006;166(16):1763-1767. [pmid: 16983056].
Rojewski MT, Korper S, Schrezenmeier H. Arsenic trioxide therapy in acute promyelocytic leukemia and beyond: From bench to bedside. Leuk Lymphoma. 2004;45(12):2387-2401. [pmid: 15621751].
Rosano GM, Marazzi G, Patrizi R, et al. Comparison of trimetazidine plus sildenafil to chronic nitrates in the control of myocardial ischemia during sexual activity in patients with coronary artery disease. Am J Cardiol. 2005;95(3):327-331. [pmid: 15670539].
Rosas-Vargas H, Coral-Vazquez RM, Tapia R, et al. Glu298Asp endothelial nitric oxide synthase polymorphism is a risk factor for erectile dysfunction in the Mexican Mestizo population. J Androl. 2004;25(5):728-732. [pmid: 15292102].
Rose VL. Sildenafil in the treatment of erectile dysfunction. Am Fam Physician. 1998;58(1):268.
Rosen RC, Kostis JB. Overview of phosphodiesterase 5 inhibition in erectile dysfunction. Am J Cardiol. 2003;92(9 SUPPL. 1):9M-18M.
Rosen RC, Lane RM, Menza M. Effects of SSRIs on sexual function: a critical review.[see comment]. [Review] [255 refs]. J Clin Psychopharmacol. 1999;19(1):67-85. [pmid: 9934946].
Rosen RC, Shabsigh R, Kuritzky L, et al. The efficacy of tadalafil in improving sexual satisfaction and overall satisfaction in men with mild, moderate, and severe erectile dysfunction: A retrospective pooled analysis of data from randomized, placebo-controlled clinical trials. Current Medical Research & Opinion. 2005;21(11):1701-1709. [pmid: 16307689].
Rosen Raymond C. Erectile dysfunction: The medicalization of male sexuality. Clin Psychol Rev. 1996;16(6):497-519.
Rosen Raymond C, Leiblum Sandra R. Treatment of male erectile disorder: Current options and dilemmas. Sexual & Marital Therapy. 1993;8(1):5-8.
Rosen Raymond C, Leiblum Sandra, Risa. Erectile disorders: An overview of historical trends and clinical perspectives. Rosen, Raymond C (Ed); Leiblum, Sandra Risa (Ed) 1992;(1992):378
Rosenthal BD, May NR, Metro MJ, et al. Adjunctive use of AndroGel (testosterone gel) with sildenafil to treat erectile dysfunction in men with acquired androgen deficiency syndrome after failure using sildenafil alone. Urology. 2006;67(3):571-574. [pmid: 16527581].
Rowland DL, Greenleaf WJ, Dorfman LJ, et al. Aging and sexual function in men. Arch Sex Behav. 1993;22(6):545-557. [pmid: 8285844].
Rowland DL, Kallan K, Slob AK. Yohimbine, erectile capacity, and sexual response in men. Arch Sex Behav. 1997;26(1):49-62. [pmid: 9015579].
Rudkin L, Taylor M J, Hawton K. Strategies for managing sexual dysfunction induced by antidepressant medication. [Review][61 refs]. Cochrane Database Syst Rev 2004;(4):CD003382
Ruof J, Graf-Morgenstern M, Mnller MJ. Quality of life in patients with erection difficulties: Evaluation of a German version of the "Quality of life measure for men with erection difficulties" (QoL-Med). Aktuel Urol. 2001;32(1):21-26.
Ryder RE, Close CF, Moriarty KT, et al. Impotence in diabetes: aetiology, implications for treatment and preferred vacuum device. Diabet Med. 1992;9(10):893-898. [pmid: 1478032].
Saad F, Grahl AS, Aversa A, et al. Effects of testosterone on erectile function: implications for the therapy of erectile dysfunction. BJU Int. 2007;99(5):988-992. [pmid: 17309554].
Saad F, Hoesl CE, Oettel M, et al. Dehydroepiandrosterone treatment in the aging male - What should the urologist know?. Eur Urol. 2005;48(5):724-733. [pmid: 16137821].
Sadock Virginia A. A sexually compulsive male with erectile dysfunction treated with Viagra: Discussion. Journal of Sex Education & Therapy. 1998;23(4):275-277.
Safarinejad MR. Prevalence and risk factors for erectile dysfunction in a population-based study in Iran. Int J Impot Res. 2003;15(4):246-252. [pmid: 12934051].
Sairam K, Kulinskaya E, Boustead GB, et al. Prevalence of undiagnosed prostate cancer in men with erectile dysfunction. BJU Int. 2002;89(3):261-263. [pmid: 11856107].
Sak SC, Eardley I. What is the relationship between benign prostatic hyperplasia and sexual function?. Sexual & Relationship Therapy. 2004;19(4):431-443.
Sakamoto H, Shimada M, Yoshida H. Hemodynamic evaluation of the penile arterial system in patients with erectile dysfunction using power doppler imaging. Urology. 2002;60(3):480-484. [pmid: 12350490].
Saks Bonnie R. A sexually compulsive male with erectile dysfunction treated with Viagra: Case report. Journal of Sex Education & Therapy. 1998;23(4):271-274.
Salonia A, Barbieri L, Chen J, et al. Comparison of the effect of sildenafil and apomorphine SL on nocturnal erections in healthy volunteers: a placebo-controlled study. Eur Urol. 2005;47(4):524-529. [pmid: 15774253].
Salonia A, Maga T, Colombo R, et al. A prospective study comparing paroxetine alone versus paroxetine plus sildenafil in patients with premature ejaculation. Br J Urol. 2002;168(6):2486-2489.
Salonia A, Rigatti P, Montorsi F. Sildenafil in erectile dysfunction: a critical review. Curr Med Res Opin. 2003;19(4):241-262. [pmid: 12841917].
Salonia Andrea, Briganti Alberto, Montorsi Piero, et al. Safety and tolerability of oral erectile dysfunction treatments in the elderly. [References]. Drugs and Aging. 2005;22(4):323-338. [pmid: 15839721].
Samarasinghe Y, Rivas-Toro H. HEART UK 18th annual medical and scientific meeting: From diabetes to mixed hyperlipidaemias. British Journal of Cardiology. 2004;11(5):364-365.
Sathe RS, Komisaruk BR, Ladas AK, et al. Naltrexone-induced augmentation of sexual response in men. Arch Med Res. 2001;32(3):221-226. [pmid: 11395188].
Sato Y, Horita H, Adachi H, et al. Effect of oral administration of prostaglandin E1 on erectile dysfunction. Br J Urol. 1997;80(5):772-775. [pmid: 9393301].
Sato Y, Suzuki N, Adachi H, et al. Evaluation of the alleviative action of neurotropin for penile pain associated with intracavernous injection of prostaglandin E1 assessed using the visual analogue scale. Int J Impot Res. 1998;10(1):1-3. [pmid: 9542683].
Savoca G, Silvestre G, Belgrano E. Intracavernosal injection therapy and surgical therapy in diabetic patients with erectile dysfunction. [Review] [26 refs]. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):53-57.
Scalvini T, Martini P R, Obici L et al. Infertility and Hypergonadotropic Hypogonadism as First Evidence of Hereditary Apolipoprotein A-I Amyloidosis. Br J Urol 2007;
Schiavi Raul C, Schanzer Harry, Sozio Giampaolo, et al. Erectile function and penile blood pressure in diabetes mellitus. J Sex Marital Ther. 1994;20(2):119-124. [pmid: 8035468].
Schimmer AD, Ali V, Stewart AK, et al. Male sexual function after autologous blood or marrow transplantation. Biology of Blood & Marrow Transplantation. 2001;7(5):279-283. [pmid: 11400950].
Scholz M, Strum S. Re: Recovery of spontaneous erectile function after nerve-sparing radical retropubic prostatectomy with and without early intracavernous injections of alprostadil: results of a prospective, randomized trial.[comment]. Br J Urol. 1999;161(6):1914-1915.
Schouman M, Lacroix P, Amer M. Suppression of prostaglandin E1-induced pain by dilution of the drug with lidocaine before intracavernous injection. Br J Urol. 1992;148(4):1266.
Schrader S, Mills A, Scheperle M, et al. Improvement in sexual functioning and satisfaction in nonresponders to testosterone gel: clinical effectiveness in hypogonadal, HIV-positive males. Clin Cornerstone. 2005;7(Suppl 4):S26-S31. [pmid: 16651205].
Schroder FH, Whelan P, De Reijke TM, et al. Metastatic prostate cancer treated by flutamide versus cyproterone acetate. Final analysis of the "European Organization for Research and Treatment of Cancer" (EORTC) Protocol 30892. Eur Urol. 2004;45(4):457-464. [pmid: 15041109].
Schultheiss D, Stief CG. Physiology and pathophysiology of erection: Consequences for present medical therapy of erectile dysfunction. Andrologia. 1999;31(SUPPL. 1):59-64. [pmid: 10643521].
Schwartz EJ, Wong P, Graydon RJ. Sildenafil preserves intracorporeal smooth muscle after radical retropubic prostatectomy. Br J Urol. 2004;171(2 I):771-774.
Seftel A. Male and female sexual function and dysfunction; andrology. Br J Urol. 2005;174(6):2297-2300.
Seftel A. Effect of lifestyle changes on erectile dysfunction in obese men. A randomized controlled trial. Br J Urol. 2005;173(2):544-545.
Seftel AD. From aspiration to achievement: Assessment and noninvasive treatment of erectile dysfunction in aging men. J Am Geriatr Soc. 2005;53(1):119-130. [pmid: 15667388].
Seftel AD. Male and female sexual function and dysfunction; andrology. Br J Urol. 2005;174(4 I):1364-1366.
Segraves RT. Pharmacological enhancement of human sexual behavior. Journal of Sex Education & Therapy. 1991;17(4):283-289.
Segraves R Taylor. Two additional uses for sildenafil in psychiatric patients. [References]. J Sex Marital Ther. 1999;25(4):265-266. [pmid: 10546163].
Segraves Robert, Taylor Segraves, Kathleen Blindt, et al. Sexual function in patients taking bupropion sustained release. Hillside J Clin Psychiatry. 1995;56(8):374.
Seidman Stuart N. Exploring the relationship between depression and erectile dysfunction in aging men. Hillside J Clin Psychiatry. 2002;63(Suppl5):5-12.
Setter SM, Iltz JL, Fincham JE, et al. Phosphodiesterase 5 inhibitors for erectile dysfunction. [Review] [75 refs]. Ann Pharmacother. 2005;39(78):1286-1295. [pmid: 15941818].
Seyam RM, Albakry A, Ghobish A, et al. Prevalence of erectile dysfunction and its correlates in Egypt: a community-based study. Int J Impot Res. 2003;15(4):237-245. [pmid: 12934050].
Shabbir M, Mikhailidis DM, Morgan RJ. Erectile dysfunction: an underdiagnosed condition associated with multiple risk factors.[comment]. Current Medical Research & Opinion. 2004;20(5):603-606. [pmid: 15140326].
Shabbir M, Shah JS, Kirby RS. Cardiac failure and benign prostatic hyperplasia: Management of common comorbidities. BJU Int. 2005;95(3):278-280. [pmid: 15679777].
Shabsigh R. Testosterone therapy in erectile dysfunction. [Review] [34 refs]. Aging Male. 2004;7(4):312-318. [pmid: 15799127].
Shabsigh R. Testosterone therapy in erectile dysfunction and hypogonadism. Br J Sex Med. 2005;2(6):785-792.
Shabsigh R. Hypogonadism and erectile dysfunction: The role for testosterone therapy. Int J Impot Res. 2003;15(SUPPL. 4):S9-S13. [pmid: 12934045].
Shabsigh R, Katz M, Yan G, et al. Cardiovascular issues in hypogonadism and testosterone therapy. [Review] [44 refs]. Am J Cardiol. 2005;96(12B):67M-72M. [pmid: 15979436].
Shakir SAW, Wilton LV, Boshier A, et al. Cardiovascular events in users of sildenafil: Results from first phase of prescription event monitoring in England. Br Med J. 2001;322(7287):651-652. [pmid: 11250850].
Shamloul R. Management of honeymoon impotence. Br J Sex Med. 2006;3(2):361-366.
Shamloul R, El-Dakhly M, Ghanem H, et al. Intracavernous chlorpromazine versus phentolamine: A double-blind clinical comparative study. Br J Sex Med. 2004;1(3):310-313.
Shamloul R, Ghanem HM, Salem A, et al. The value of penile duplex in the prediction of intracavernous drug-induced priapism. Int J Impot Res. 2004;16(1):78-79. [pmid: 14961063].
Shamsa A, Motavalli SM, Aghdam B. Erectile function in end-stage renal disease before and after renal transplantation. Transplant Proc. 2005;37(7):3087-3089. [pmid: 16213314].
Sharlip ID. Editorial comment. International Braz J Urol. 2005;31(4):354-355.
Sharlip I D. Can self-injection therapy cure impotence?. [Review] [7 refs]. Advances in Experimental Medicine & Biology. 1997;43:383-86.
Shimon I, Lubina A, Gorfine M, et al. Feedback inhibition of gonadotropins by testosterone in men with hypogonadotropic hypogonadism: comparison to the intact pituitary-testicular axis in primary hypogonadism. J Androl. 2006;27(3):358-364. [pmid: 16474013].
Siegel RL, Dubin NH, Andrade JR. Sildenafil citrate and sperm function [3] (multiple letters). American Journal of Obstetrics & Gynecology. 2001;184(4):777-778. [pmid: 11262489].
Sighinolfi MC, de Stefani S, Mofferdin A, et al. Intracavernous prostaglandin E1 infusion in diabetes with associated ischemic necrosis of the glans penis. Br J Urol. 2004;171(6 I):2380.
Silvestri A, Galetta P, Cerquetani E, et al. Report of erectile dysfunction after therapy with beta-blockers is related to patient knowledge of side effects and is reversed by placebo.[see comment]. Eur Heart J. 2003;24(21):1928-1932. [pmid: 14585251].
Singer Carlos, Weiner William J, Sanchez-Ramos J, et al. Sexual function in patients with Parkinson's disease. Journal of Neurology, Neurosurgery & Psychiatry. 1991;54(10):942.
Sipski M, Alexander C, Guo X, et al. Cardiovascular effects of sildenafil in men with SCIs at and above T6. Topics in Spinal Cord Injury Rehabilitation. 2003;8(3):26-34.
Siraj QH, Bomanji J, Akhtar MA, et al. Quantitation of pharmacologically-induced penile erections: The value of radionuclide phallography in the objective evaluation of erectile haemodynamics. Nucl Med Commun. 1990;11(6):445-458. [pmid: 2385430].
Slob AK, Dohle GR, Incrocci L. ‘Sildenafil and pharmaco-penile duplex ultrasonography’ by Speel et al: Inconclusive results. Int J Impot Res. 2002;14(2):136-137. [pmid: 11979331].
Slob A, Koos Steyvers, Christel L, et al. Routine psychophysiological screening of 384 men with erectile dysfunction. J Sex Marital Ther. 1998;24(4):273-279. [pmid: 9805287].
Smith KJ, Roberts MS. The cost-effectiveness of sildenafil. Ann Intern Med. 2000;132(12):933-937. [pmid: 10858175].
Smith KM, Romanelli F. Recreational use and misuse of phosphodiesterase 5 inhibitors. [Review] [56 refs]. Journal of the American Pharmacists Association: JAPhA. 2005;45(1):63-72. [pmid: 15730119].
Sobh MA, Abd el, Hamid I, et al. Effect of erythropoietin on sexual potency in chronic haemodialysis patients. A preliminary study. Scand J Urol Nephrol. 1992;26(2):181-185. [pmid: 1626208].
Sogari PR, Teloken C, Souto CA. Atropine role in the pharmacological erection test: study of 228 patients. Br J Urol. 1997;158(5):1760-1763.
Sohle GR. Re: The age-related decrease in testosterone is significantly exacerbated in obese men with the metabolic syndrome. What are the implications for the relatively high incidence of erectile dysfunction observed in these men?. Eur Urol. 2007;51(5):1440. [pmid: 17494117].
Sohn Michael, Sikora Richard. Ginkgo biloba extract in the therapy of erectile dysfunction. Journal of Sex Education & Therapy. 1991;17(1):53-61.
Solursh L, Solursh DS. Male erectile disorders in Vietnam combat veterans with chronic post-traumatic stress disorder. International Journal of Adolescent Medicine & Health. 1994;7(2):119-124. [pmid: 22912152].
Solursh Lionel P, Solursh Diane S. Male erectile disorders in Vietnam combat veterans with chronic post-traumatic stress disorder. Int J Adolesc Med Health. 1994;7(2):119-124. [pmid: 22912152].
Sonda LP, Mazo R, Chancellor MB. The role of yohimbine for the treatment of erectile impotence. J Sex Marital Ther. 1990;16(1):15-21. [pmid: 2370671].
Sonksen J, Biering-Sorensen F. Transcutaneous nitroglycerin in the treatment of erectile dysfunction in spinal cord injured. Paraplegia. 1992;30(8):554-557. [pmid: 1522996].
Sorbera LA, Martin L, Rabasseda X, et al. Vardenafil. Treatment of erectile dysfunction. Phosphodiesterase 5 inhibitor. Drugs of the Future. 2001;26(2):141-144.
Sparwasser C, Drescher P, Pust RA, et al. Long-term results of therapy with intracavernousal injections and penile venous surgery in chronic erectile dysfunction. Scand J Urol Nephrol Suppl. 1994;157(Suppl):107-112. [pmid: 7939440].
Speakman MT, Kloner RA. Viagra and cardiovascular disease. Journal of Cardiovascular Pharmacology & Therapeutics. 1999;4(4):259-267. [pmid: 10684547].
Srilatha B, Adaikan PG, Chong YS. Relevance of oestradiol-testosterone balance in erectile dysfunction patients' prognosis. Singapore Med J. 2007;48(2):114-118. [pmid: 17304389].
Stas SN, Anastasiadis AG, Fisch H, et al. Urologic aspects of andropause. Urology. 2003;61(2):261-266. [pmid: 12597927].
Steers WD. Tachyphylaxis and phosphodiesterase type 5 inhibitors.[comment]. Br J Urol. 2002;168(1):207.
Steers WD. Viagra - After one year. Urology. 1999;54(1):12-17. [pmid: 10414719].
Steidle C, Witt MA, Matrisciano J, et al. Sexual functioning and satisfaction in nonresponders to testosterone gel: Potential effectiveness of retreatment in hypogonadal males. Clin Cornerstone. 2005;7(Suppl 4):S20-S25. [pmid: 16651204].
Steiger A, Holsboer F, Benkert O. Studies of nocturnal penile tumescence and sleep electroencephalogram in patients with major depression and in normal controls. Acta Psychiatr Scand. 1993;87(5):358-363. [pmid: 8517177].
Steiger Axel, Benkert O, Holsboer F. Effects of long-term treatment with the MAO-A inhibitor moclobemide on sleep EEG and nocturnal hormonal secretion in normal men. Neuropsychobiology. 1994;30(23):101-105. [pmid: 7800155].
Stief CG, Uckert S, Jonas U. Strategies in the oral pharmacotherapy of male erectile dysfunction viewed from bench and bedside (Part II). The Journal of Mens Health & Gender. 2005;2(3):325-332.
Stief CG, Uckert S, Becker AJ, et al. The effect of the specific phosphodiesterase (PDE) inhibitors on human and rabbit cavernous tissue in vitro and in vivo. Br J Urol. 1998;159(4):1390-1393.
Stief C, Padley RJ, Perdok RJ, et al. Cross-study review of the clinical efficacy of apomorphine SL 2 and 3 mg: Pooled data from three placebo-controlled, fixed-dose crossover studies. European Urology Supplements. 2002;1(3):12-20.
Stolk EA, Busschbach JJ, Caffa M, et al. Cost utility analysis of sildenafil compared with papaverine-phentolamine injections.[see comment]. BMJ. 2000;320(7243):1165-1168. [pmid: 10784537].
Strachan MW, Teoh WL, Don-Wauchope AC, et al. Clinical and radiological features of patients with macroprolactinaemia. Clin Endocrinol (Oxf). 2003;59(3):339-346. [pmid: 12919157].
Strahilevitz J, Rahav G, Schroers HJ, et al. An outbreak of Phialemonium infective endocarditis linked to intracavernous penile injections for the treatment of impotence. Clin Infect Dis. 2005;40(6):781-786. [pmid: 15736008].
Stroberg P, Murphy A, Costigan T. Switching patients with erectile dysfunction from sildenafil citrate to tadalafil: results of a European multicenter, open-label study of patient preference. Clin Ther. 2003;25(11):2724-2737. [pmid: 14693300].
Struthers AD. Aldosterone blockade in heart failure. J Renin Angiotensin Aldosterone Syst. 2004;5(SUPPL. 1):S23-S27. [pmid: 15526239].
Stuckey BGA. Tadalafil phase 3 experience. European Urology Supplements. 2002;1(8):25-30.
Suetomi T, Endo F, Takeshima H, et al. Evaluation of the effectiveness of sildenafil using questionnaire methods versus audio-visual sexual stimulation. Int J Urol. 2005;12(4):369-373. [pmid: 15948724].
Suzuki F, Shimizu C, Umetsu M, et al. Adult-onset idiopathic hypogonadotropic hypogonadism due to isolated pituitary gonadotropin deficiency. Adv Intern Med. 2004;43(7):571-574.
Svartberg J, Aasebo U, Hjalmarsen A, et al. Testosterone treatment improves body composition and sexual function in men with COPD, in a 6-month randomized controlled trial. Respir Med. 2004;98(9):906-913. [pmid: 15338805].
Swartz DA, Todd MW. Intracavernous papaverine and glaucoma.[see comment]. JAMA. 1990;264(5):570. [pmid: 2366292].
Szucs A, Janszky J, Barsi P, et al. Sleep-related painful erection is associated with neurovascular compression of basal forebrain [5]. J Neurol. 2002;249(4):486-487. [pmid: 11967660].
T'Sjoen G, Feyen E, De Kuyper P, et al. Self-referred patients in an aging male clinic: much more than androgen deficiency alone. Aging Male. 2003;6(3):157-165. [pmid: 14628496].
Tam SW, Worcel M, Wyllie M. Yohimbine: a clinical review. [Review] [152 refs]. Pharmacol Ther. 2001;91(3):215-243. [pmid: 11744068].
Tarhan F, Canguven O, Kuyumcuoglu U. Intracavernous sodium nitroprusside (SNP) versus papaverine/phentolamine in erectile dysfunction: a comparative study of short-term efficacy and side-effects.[comment]. Br J Sex Med. 2006;3(2):377.
Tarhan F, Kuyumcuoglu U, Kolsuz A, et al. Effect of intracavernosal sodium nitroprusside in impotence. Urol Int. 1996;56(4):211-214. [pmid: 8776816].
Tas A, Dilek K, Gullulu M et al. Treatment of erectile dysfunction in hemodialysis patients and effects of sildenafil [abstract]. XXXVIII Congress of the European Renal Association European Dialysis & Transplant Association June 24–27 2003;2001, Vienna, Austria 131p. 2003.
Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005;88(3):241-254. [pmid: 16162361].
Teillac P, Bono AV, Irani J, et al. The role of luteinizing hormone-releasing hormone therapy in locally advanced prostate cancer and biochemical failure: Considerations for optimal use. Clin Ther. 2005;27(3):273-285. [pmid: 15878381].
Teloken PE, Smith EB, Lodowsky C, et al. Defining association between sleep apnea syndrome and erectile dysfunction. Urology. 2006;67(5):1033-1037. [pmid: 16698364].
Thadani U, Smith W, Nash S, et al. The effect of vardenafil, a potent and highly selective phosphodiesterase-5 inhibitor for the treatment of erectile dysfunction, on the cardiovascular response to exercise in patients with coronary artery disease. J Am Coll Cardiol. 2002;40(11):2006-2012. [pmid: 12475462].
Thaveundayil JX, Hambalek R, Ng Ying, et al. Prolonged penile erections induced by hydroxyzine: Possible mechanism of action. Neuropsychobiology. 1994;30(1):4-6. [pmid: 7969858].
Thrasher JB. What's new in urology. J Am Coll Surg. 2005;201(3):438-448. [pmid: 16125079].
Tindall B, Forde S, Goldstein D, et al. Sexual dysfunction in advanced HIV disease. AIDS Care. 1994;6(1):105-107. [pmid: 8186272].
Tomlinson J. Viagra and its use in cardiovascular disease.[erratum appears in J Hum Hypertens 2000 Apr;14(4):283]. [Review] [11 refs]. J Hum Hypertens. 1999;13(9):593-594. [pmid: 10482968].
Tomova A, Kumanov P. Are dehydroepiandrosterone sulphate and lipids associated with erectile dysfunction? [References]. Maturitas. 2005;50(4):294-299. [pmid: 15780529].
Tordjman G. NO/Pg E1: a new association in the treatment of erectile impotence. Contracept Fertil Sex (Paris) 1993;.21, pp.509–510, 1993.
Tosti A, Pazzaglia M, Soli M, et al. Evaluation of sexual function with an international index of erectile function in subjects taking finasteride for androgenetic alopecia.[see comment]. Arch Dermatol. 2004;140(7):857-858. [pmid: 15262698].
Traish AM, Goldstein I, Kim NN. Testosterone and erectile function: from basic research to a new clinical paradigm for managing men with androgen insufficiency and erectile dysfunction. Eur Urol. 2007;52(1):54-70. [pmid: 17329016].
Trinchieri A, Nicola M, Masini F, et al. Prospective comprehensive assessment of sexual function after retropubic non nerve sparing radical prostatectomy for localized prostate cancer. Arch Ital Urol Androl. 2005;77(4):219-223. [pmid: 16444937].
Truss MC, Becker AJ, Djamilian MH, et al. Role of the nitric oxide donor linsidomine chlorhydrate (SIN-1) in the diagnosis and treatment of erectile dysfunction. Urology. 1994;44(4):553-556. [pmid: 7941195].
Tsai SK, Hong CY. Intracavernosal metaraminol for treatment of intraoperative penile erection. Postgrad Med J. 1990;66(780):831-833. [pmid: 2099422].
Tsujimura A, Matsumiya K, Matsuoka Y, et al. Bioavailable testosterone with age and erectile dysfunction. Br J Urol. 2003;170(6 Pt 1):2345-2347.
Tuzgen S, Karamehmetoglu SS, Karacan I, et al. Use of sildenafil in the treatment of erectile dysfunction in patients with spinal cord injury. Neurosurgery Quarterly. 2006;16(1):40-43.
Tzivoni D, Klein J, Hisdai D, et al. The Israel Heart Society expert consensus document: The cardiac patient and sexual activity in the era of sildenafil (Viagra). Israel Medical Association Journal: Imaj. 2000;2(1):63-65. [pmid: 10892379].
Unnikrishnan AG, Rajaratnam S, Seshadri MS, et al. The ‘hook effect’ on serum prolactin estimation in a patient with macroprolactinoma. Neurol India. 2001;49(1):78-80. [pmid: 11303248].
Urciuoli R, Cantisani T A, CarliniI M et al. Prostaglandin E1 for treatment of erectile dysfunction. Cochrane Database Syst Rev 2004;(2):CD001784
Uygur MC, Arik AI, Altug U, et al. Effects of the 5 alpha-reductase inhibitor finasteride on serum levels of gonadal, adrenal, and hypophyseal hormones and its clinical significance: a prospective clinical study. Steroids. 1998;63(4):208-213. [pmid: 9589555].
Valdevenito R, Melman A. Intracavernous self-injection pharmacotherapy program: analysis of results and complications. Int J Impot Res. 1994;6(2):81-91. [pmid: 7951702].
van Basten JP, Van Driel MF, Hoekstra HJ, et al. Erectile dysfunction with chemotherapy.[comment]. Lancet. 2000;356(9224):169. [pmid: 10963279].
van Basten JP, Van Driel MF, Hoekstra HJ, et al. Erectile dysfunction with chemotherapy. Lancet. 2000;356(9224):169. [pmid: 10963279].
van Basten JP, Van Driel MF, Jonker-Pool G, et al. Sexual functioning in testosterone-supplemented patients treated for bilateral testicular cancer. Br J Urol. 1997;79(3):461-467. [pmid: 9117232].
Van Ahlen H, Peskar BA, Sticht G, et al. Pharmacokinetics of vasoactive substances administered into the human corpus cavernosum. Br J Urol. 1994;151(5):1227-1230.
Van Dijk M, Skrekas T, De La, et al. The association between lower urinary tract symptoms and sexual dysfunction: Fact or fiction?. Curr Opin Urol. 2005;15(1):39-44. [pmid: 15586029].
Van Moorselaar J. LUTS and Sexual Dysfunction: Implications for Management of BPH. European Urology Supplements. 2003;2(10):13-20.
Vardi M, Nini A. Phosphodiesterase inhibitors for erectile dysfunction in patients with diabetes mellitus. [Review][49 refs]. Cochrane Database Syst Rev 2007;(1):CD002187
Vatansever HS, Kayikcioglu O, Gumus B. Histopathologic effect of chronic use of sildenafil citrate on the choroid & retina in male rats. Indian J Med Res. 2003;117(MAY):211-215. [pmid: 14609049].
Verit A, Oguz H. Ophthalmic aspects of erectile dysfunction drugs [3]. Am J Ophthalmol. 2006;141(3):598. [pmid: 16490529].
Vick RN, Benevides M, Patel M, et al. The efficacy, safety and tolerability of intracavernous PNU-83757 for the treatment of erectile dysfunction. Br J Urol. 2002;167(6):2618-2623.
Vickers MA, De Nobrega AM, Dluhy RG. Diagnosis and treatment of psychogenic erectile dysfunction in a urological setting: Outcomes of 18 consecutive patients. Br J Urol. 1993;149(5 SUPPL.):1258-1261.
Vickers MA, Wright EA. Erectile dysfunction in the patient with diabetes mellitus. Am J Manag Care. 2004;10(1 SUPPL.):S3-S11. [pmid: 14974584].
Vidal J, Curcoll L, Roig T, et al. Intracavernous pharmacotherapy for management of erectile dysfunction in multiple sclerosis patients. Rev Neurol. 1995;23(120):269-271. [pmid: 7497173].
Vinik AI, Maser RE, Mitchell BD, et al. Diabetic autonomic neuropathy. [Review] [192 refs]. Diabetes Care. 2003;26(5):1553-1579. [pmid: 12716821].
Virag R. Intracavernous injection of papaverine for erectile failure. 1982. Br J Urol. 2002;167(2 Pt 2):1196.
Virag R, Floresco J, Richard C. Impairment of shear-stress-mediated vasodilation of cavernous arteries in erectile dysfunction. Int J Impot Res. 2004;16(1):39-42. [pmid: 14963469].
Vitezic D. A risk-benefit assessment of sildenafil in the treatment of erectile dysfunction. [Review] [72 refs]. Drug Saf. 2001;24(4):255-265. [pmid: 11330655].
Vlachopoulos C, Hirata K, O'Rourke MF. Effect of sildenafil on arterial stiffness and wave reflection. Vasc Med. 2003;8(4):243-248. [pmid: 15125484].
Vogt HJ, Brandl P, Kockott G, et al. Double-blind, placebo-controlled safety and efficacy trial with yohimbine hydrochloride in the treatment of nonorganic erectile dysfunction. Int J Impot Res. 1997;9(3):155-161. [pmid: 9315493].
Wagner G, Mulhall J. Pathophysiology and diagnosis of male erectile dysfunction. BJU International - Supplement. 2001;88(3):3-10.
Wagner G, Rabkin J, Rabkin R. Effects of testosterone replacement therapy on sexual interest, function, and behavior in HIV+ men. J Sex Res. 1997;34(1):27-33.
Wagner Gorm, Kaplan Helen, Singer. The new injection treatment for impotence: Medical and psychological aspects. Refuat Hapeh Vehashinayim 1993;x, 210 pp. Philadelphia, PA, US210
Wagrell L, Schelin S, Nordling J, et al. Three-year follow-up of feedback microwave thermotherapy versus TURP for clinical BPH: a prospective randomized multicenter study. Urology. 2004;64(4):698-702. [pmid: 15491704].
Wald M, Seftel AD, Ross LS, et al. Computational models for detection of erectile dysfunction. Br J Urol. 2005;173(1):167-170.
Waldbaum RS. The safety of PDE5 inhibitors in ED treatment: Putting cardiovascular concerns to rest. Cardiology Review. 2005;22(9):23-24.
Wang ZL, Shao SX, Li B, et al. Sildenafil versus prostaglandin E1 in the management of erectile dysfunction. Journal of Clinical Urology. 2002;17(7):347-349.
Wang Z, Liu BC, Chen B, et al. Randomized controlled study on erectile dysfunction treated by trazodone. Chinese Journal of Andrology. 2002;16(3):236-238.
Ware J, Catesby Rose F, Vincent McBrayer, et al. The acute effects of nefazodone, trazodone and buspirone on sleep and sleep-related penile tumescence in normal subjects. Sleep: Journal of Sleep Research & Sleep Medicine. 1994;17(6):544-550.
Watanabe T, Chancellor MB, Rivas DA, et al. Epidemiology of current treatment for sexual dysfunction in spinal cord injured men in the USA model spinal cord injury centers. J Spinal Cord Med. 1996;19(3):186-189. [pmid: 8819027].
Webb DJ, Freestone S, Allen MJ, et al. Sildenafil citrate and blood-pressure-lowering drugs: results of drug interaction studies with an organic nitrate and a calcium antagonist. Am J Cardiol. 1999;83(5A):21C-28C. [pmid: 10073779].
Webb DJ, Muirhead GJ, Wulff M, et al. Sildenafil citrate potentiates the hypotensive effects of nitric oxide donor drugs in male patients with stable angina. J Am Coll Cardiol. 2000;36(1):25-31. [pmid: 10898408].
Wegner HEH, Knispel HH, Meier T, et al. Nitric oxide donor, linsidomine chlorhydrate (SIN-1), in the diagnosis and treatment of erectile dysfunction: Critical appraisal and review of the literature. International Urology & Nephrology. 1995;27(5):621-628. [pmid: 8775048].
Weinhardt LS, Carey MP. Prevalence of erectile disorder among men with diabetes mellitus: Comprehensive review, methodological critique, and suggestions for future research. J Sex Res. 1996;33(3):205-214.
Weinsaft JW, Hickey K, Bokhari S, et al. Effects of tadalafil on myocardial blood flow in patients with coronary artery disease. Coron Artery Dis. 2006;17(6):493-499. [pmid: 16905960].
Weiske WH. Invasive diagnosis and therapy - Are they still reasonable in the age of sildenafil?. Andrologia. 1999;31(SUPPL. 1):95-97. [pmid: 10643526].
Wespes E, Rammal A, Garbar C. Sildenafil non-responders: haemodynamic and morphometric studies. Eur Urol. 2005;48(1):136-139. [pmid: 15967263].
Wessells H, Fuciarelli K, Hansen J, et al. Synthetic melanotropic peptide initiates erections in men with psychogenic erectile dysfunction: double-blind, placebo controlled crossover study. Br J Urol. 1998;160(2):389-393.
Wessells H, Gralnek D, Dorr R, et al. Effect of an alpha-melanocyte stimulating hormone analog on penile erection and sexual desire in men with organic erectile dysfunction. Urology. 2000;56(4):641-646. [pmid: 11018622].
Wheatley D. Triple-blind, placebo-controlled trial of Ginkgo biloba in sexual dysfunction due to antidepressant drugs. Hum Psychopharmacol. 2004;19(8):545-548. [pmid: 15378664].
Wilke DR, Parker C, Andonowski A, et al. Testosterone and erectile function recovery after radiotherapy and long-term androgen deprivation with luteinizing hormone-releasing hormone agonists. BJU Int. 2006;97(5):963-968. [pmid: 16542340].
Williams G. Male erectile dysfunction. Prescribers' Journal. 2000;40(1):49-58.
Williams T, Honeywell M, Branch E et al. Tadalafil in the treatment of erectile dysfunction. P & T 2004;29(5):
Wilt TJ, Fink HA. Is antidepressant plus sildenafil a recipe for priapism?. Postgrad Med. 2004;116(6):11-12. [pmid: 15620123].
Witt Deborah K. Yohimbine for erectile dysfunction. J Fam Pract. 1998;46(4):282-283. [pmid: 9564368].
Wood P L. Slow, tedious but essential: The need for incremental R&D. Current Drug Discovery 2004;(pp 31–35):-35.
Wyllie MG. The hunt for pink Viagra. BJU Int. 2005;95(1):181-182. [pmid: 15638919].
Wyllie MG. Let's hope for more in 2004. BJU Int. 2004;93(1):175-176. [pmid: 14678392].
Wyllie MG. The Second International Consultation on Erectile Dysfunction: Highlights from the pharmaceutical industry. BJU Int. 2003;92(6):645-646. [pmid: 14511053].
Wyllie MG. The genesis of a phytopharmaceutical industry (Mark II). BJU Int. 2003;91(7):721-722. [pmid: 12699492].
Yajima T, Yajima Y, Koppiker N, et al. No clinically important effects on intraocular pressure after short-term administration of sildenafil citrate (Viagra). Am J Ophthalmol. 2000;129(5):675-676. [pmid: 10844068].
Yaman O, Akand M, Gursoy A, et al. The effect of diabetes mellitus treatment and good glycemic control on the erectile function in men with diabetes mellitus-induced erectile dysfunction: a pilot study. Br J Sex Med. 2006;3(2):344-348.
Yaman O, Tokatli Z, Akand M, et al. Characteristics of sildenafil erections in healthy young men. Asian J Androl. 2005;7(4):395-398. [pmid: 16281087].
Yamanaka M, Shirai M, Shiina H, et al. Vascular endothelial growth factor restores erectile function through inhibition of apoptosis in diabetic rat penile crura. Br J Urol. 2005;173(1):318-323.
Yan JY, Yang WZ. A comparative effects of Sildenafil and Yohimbine for the treatment of erectile dysfunction. Chinese Journal of Andrology. 2000;14(2):103-105.
Yarkony GM. Enhancement of sexual function and fertility in spinal cord-injured males. [Review] [40 refs]. Am J Phys Med Rehabil. 1990;69(2):81-87. [pmid: 2184843].
Yassin AA, Saad F. Treatment of sexual dysfunction of hypogonadal patients with long-acting testosterone undecanoate (Nebido). [Review] [25 refs]. World J Urol. 2006;24(6):639-644. [pmid: 17048032].
Yassin AA, Saad F. Dramatic improvement of penile venous leakage upon testosterone administration. A case report and review of literature. Andrologia. 2006;38(1):34-37. [pmid: 16420241].
Yasumoto R, Nishisaka N, Sakakura T, et al. Ethanol embolization for impotent patients with venous leakage: A new technique and initial results. Minimally Invasive Therapy & Allied Technologies: Mitat. 1996;5(6):564-566.
Yeager J, Beihn RM. Retention and migration of alprostadil cream applied topically to the glans meatus for erectile dysfunction. Int J Impot Res. 2005;17(1):91-95. [pmid: 15538395].
Youssef AF, Fort FL, Ronsen B, et al. Evaluation of apomorphine HCl effects on reproductive endpoints: Studies in male rats and dogs. J Toxicol Sci. 1999;51(2):273-279.
Zaslau S, Nicolis C, Galea G, et al. A simplified pharmacologic erection program for patients with spinal cord injury. J Spinal Cord Med. 1999;22(4):303-307. [pmid: 10751135].
Zasler ND. Therapeutic approaches to sexual impotence. Hospital Practice (Office Edition). 1988;23(7):197-200.
Zhao L. Clinical observation on the therapeutic effects of heavy moxibustion plus point-injection in treatment of impotence. J Tradit Chin Med. 2004;24(2):126-127. [pmid: 15270266].
Zhigang Long, Xiaowei Liu, Shengbo Lu. Therapy of impotence with traditional Chinese medicine. Journal of Sex Education & Therapy. 1994;20(2):140-143.
Ziegler D. Management of erectile dysfunction in diabetic patients. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):58-65.
Zini Dante, Carani Cesare, Baldini Augusto, et al. Sexual behavior of men with isolated hypogonadotropic hypogonadism or prepubertal anterior panhypopituitarism. Horm Behav. 1990;24(2):174-185. [pmid: 2365300].
Zlotta AR, Teillac P, Raynaud JP, et al. Evaluation of male sexual function in patients with Lower Urinary Tract Symptoms (LUTS) associated with Benign Prostatic Hyperplasia (BPH) treated with a phytotherapeutic agent (Permixon), Tamsulosin or Finasteride. Eur Urol. 2005;48(2):269-276. [pmid: 15939527].
Zusman RM. Cardiovascular data on sildenafil citrate: introduction.[erratum appears in Am J Cardiol 1999 Jul 15;84(2):244]. Am J Cardiol. 1999;83(5A):1C-2C. [pmid: 10073775].
Zusman RM, Morales A, Glasser DB, et al. Overall cardiovascular profile of sildenafil citrate. [Review] [33 refs]. Am J Cardiol. 1999;83(5A):35C-44C.
Zusman RM, Prisant LM, Brown MJ. Effect of sildenafil citrate on blood pressure and heart rate in men with erectile dysfunction taking concomitant antihypertensive medication. Sildenafil Study Group. J Hypertens. 2000;18(12):1865-1869. [pmid: 11132612].

## Observational injection study with < 6 months followup in duration

Bancroft J, Smith G, Munoz M, et al. Erectile response to visual erotic stimuli before and after intracavernosal papaverine, and its relationship to nocturnal penile tumescence and psychometric assessment. Br J Urol. 1991;68(6):629-638. [pmid: 1773296].
Beretta G, Marzotto M, Zanollo A, et al. Office treatment: intracavernous injections of prostaglandin E1 (PG E1) and improvement of spontaneous erections. Acta Eur Fertil. 1991;22(4):221-223. [pmid: 1844326].
Bird TD, Lipe HP, Crabtree LD. Impotence associated with the Charcot-Marie-Tooth syndrome. Eur Neurol. 1994;34(3):155-157. [pmid: 8033941].
Brown SL, Haas CA, Koehler M, et al. Hepatotoxicity related to intracavernous pharmacotherapy with papaverine. Urology. 1998;52(5):844-847. [pmid: 9801111].
Casella R, Deckart A, Bachmann A, et al. The patient's self-evaluation better predicts the degree of erectile dysfunction than the response to intracavernous alprostadil testing. Urol Int. 2004;72(3):216-220. [pmid: 15084765].
Chatterjee R, Kottaridis PD, McGarrigle HH, et al. Management of erectile dysfunction by combination therapy with testosterone and sildenafil in recipients of high-dose therapy for haematological malignancies. Bone Marrow Transplant. 2002;29(7):607-610. [pmid: 11979311].
Chun SS, Fenemore J, Heaton JP, et al. Enhancement of erectile responses to vasoactive drugs by a variable amplitude oscillation device. Int J Impot Res. 1996;8(4):221-225. [pmid: 8981171].
Dinsmore WW, Alderdice DK. Vasoactive intestinal polypeptide and phentolamine mesylate administered by autoinjector in the treatment of patients with erectile dysfunction resistant to other intracavernosal agents. Br J Urol. 1998;81(3):437-440. [pmid: 9523666].
Fein RL. Classification of sexual dysfunction for management of intracavernous medication-induced erections.[see comment]. Br J Urol. 1990;143(2):298-301.
Goonawardena SA, de Silva WA, Ketheeswaran T. Pharmacologically induced penile erections in the assessment and treatment of erectile impotence: a preliminary study of 100 patients. Ceylon Med J. 1997;42(2):72-74. [pmid: 9257465].
Greco E, Balbi PP, Virag R. Self intra-cavernous injections as a successful treatment in pure neurogenic impotence. Riv Neurol. 1991;61(1):35-38. [pmid: 1857921].
Kadioglu A, Erdogru T, Tellaloglu S. Combined intracavernous injection of papaverine and stimulation (CIS) test. J Androl. 1994;15(Suppl):50S-53S. [pmid: 7721678].
Katlowitz NM, Albano GJ, Morales P, et al. Potentiation of drug-induced erection with audiovisual sexual stimulation. Urology. 1993;41(5):431-434. [pmid: 8488610].
Katlowitz N, Albano GJ, Patsias G, et al. Effect of multidose intracorporeal injection and audiovisual sexual stimulation in vasculogenic impotence. Urology. 1993;42(6):695-697. [pmid: 8256402].
Kim JM, Joh YD, Huh JD, et al. Doppler sonography of the penile cavernosal artery: comparison of intraurethral instillation and intracorporeal injection of prostaglandin E1. J Clin Ultrasound. 2001;29(5):273-278. [pmid: 11486321].
Knispel HH. Penile venous surgery in impotence: results in highly selected cases. Urol Int. 1991;47(3):144-148. [pmid: 1771702].
Kromann-Andersen B. Intracavernosal pharmacotherapy with injection pen. Lancet. 1988;1(85756):54-59. [pmid: 2891913].
Mansi MK, Alkhudair WK, Huraib S. Treatment of erectile dysfunction after kidney transplantation with intracavernosal self-injection of prostaglandin E1. Br J Urol. 1998;159(6):1927-1930.
McMahon CG. A pilot study of the role of intracavernous injection of vasoactive intestinal peptide (VIP) and phentolamine mesylate in the treatment of erectile dysfunction. Int J Impot Res. 1996;8(4):233-236. [pmid: 8981173].
McMahon CG. Priapism associated with concurrent use of phosphodiesterase inhibitor drugs and intracavernous injection therapy. Int J Impot Res. 2003;15(5):383-384. [pmid: 14562142].
Metawea B, El-Nashar AR, Gad-Allah A, et al. Intracavernous papaverine/phentolamine-induced priapism can be accurately predicted with color Doppler ultrasonography. Urology. 2005;66(4):858-860. [pmid: 16230153].
Mirone V, Imbimbo C, Fabrizio F, et al. Ketanserin plus prostaglandin E1 (PGE-1) as intracavernosal therapy for patients with erectile dysfunction unresponsive to PGE-1 alone. Br J Urol. 1996;77(5):736-739. [pmid: 8689122].
Nagai A, Kusumi N, Tsuboi H, et al. Intracavernous injection of prostaglandin E1 is effective in patients with erectile dysfunction not responding to phosphodiseterase 5 inhibitors. Acta Med Okayama. 2005;59(6):279-280. [pmid: 16418771].
Nalesnik JG, Jones L, Kraus SR. Group B streptococcal septicemia following intracavernous injection therapy for erectile dysfunction in diabetes. Br J Urol. 2004;172(1):151-152.
Pagani E, Puech-Leao P, Glina S, et al. The value of a second injection on the pharmaco-induced erection test. Int J Impot Res. 1997;9(3):167-168. [pmid: 9315495].
Price DE, Cooksey G, Jehu D, et al. The management of impotence in diabetic men by vacuum tumescence therapy. Diabet Med. 1991;8(10):964-967. [pmid: 1838050].
Rodilla F, Fuentes MD, Chuan P, et al. Penile self-injection for impotence in patients after radical cystectomy. Journal of Clinical Pharmacy & Therapeutics. 1994;19(6):359-360. [pmid: 7876367].
Rodrigues M, Granegger S, O'Grady J, et al. Accumulation of platelets as a key mechanism of human erection. A scintigraphic study in patients with erectile dysfunction receiving intracavernous injection of PGE1, papaverine/phentolamine. Advances in Experimental Medicine & Biology. 1997;43:379-82.
Schouman M, Lacroix P, Amer M. Suppression of prostaglandin E1-induced pain by dilution of the drug with lidocaine before intracavernous injection. Br J Urol. 1992;148(4):1266.
Sparwasser C, Treiber U, Bahren W, et al. Postoperative erectile dysfunction; evaluation and treatment with intracavernous vasoactive injections. Progress in Clinical & Biological Research. 1991;370:349-354. [pmid: 1924468].
Stief CG, Holmquist F, Djamilian M, et al. Preliminary results with the nitric oxide donor linsidomine chlorhydrate in the treatment of human erectile dysfunction. Br J Urol. 1992;148(5):1437-1440.
Stief CG, Wetterauer U, Schaebsdau FH, et al. Calcitonin-gene-related peptide: a possible role in human penile erection and its therapeutic application in impotent patients. Br J Urol. 1991;146(4):1010-1014.
Vickers MA, De Nobrega AM, Dluhy RG. Diagnosis and treatment of psychogenic erectile dysfunction in a urological setting: Outcomes of 18 consecutive patients. Br J Urol. 1993;149(5 SUPPL.):1258-1261.
Weiss JN, Ravalli R, Badlani GH. Intracavernous pharmacotherapy in psychogenic impotence. Urology. 1991;37(5):441-443. [pmid: 1708925].

## Observational injection study > or = to 6 months in duration

al-Juburi AZ, O'Donnell PD. Follow up outcome of intracavernous papaverine. J Ark Med Soc. 1990;86(10):383-385. [pmid: 2138146].
Armstrong DK, Convery AG, Dinsmore WW. Reasons for patient drop-out from an intracavernous auto-injection programme for erectile dysfunction. Br J Urol. 1994;74(1):99-101. [pmid: 8044533].
Chang DW, Wood CG, Kroll SS, et al. Cavernous nerve reconstruction to preserve erectile function following non-nerve-sparing radical retropubic prostatectomy: a prospective study. Keisei Geka. 2003;111(3):1174-1181.
Chen J, Godschalk MF, Katz PG, et al. Incidence of penile pain after injection of a new formulation of prostaglandin E1.[see comment]. Br J Urol. 1995;154(1):77-79.
Chen J, Godschalk MF, Katz PG, et al. Combining intracavernous injection and external vacuum as treatment for erectile dysfunction.[see comment]. Br J Urol. 1995;153(5):1476-1477.
Cooper AJ. Evaluation of I-C papaverine in patients with psychogenic and organic impotence. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 1991;36(8):574-578. [pmid: 1742710].
Dhabuwala CB, Kerkar P, Bhutwala A, et al. Intracavernous papaverine in the management of psychogenic impotence. Arch Androl. 1990;24(2):185-191. [pmid: 2327828].
Fedele D, Coscelli C, Cucinotta D, et al. Management of erectile dysfunction in diabetic subjects: results from a survey of 400 diabetes centres in Italy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14(5):277-282.
Fein RL. Classification of sexual dysfunction for management of intracavernous medication-induced erections.[see comment]. Br J Urol. 1990;143(2):298-301.
Fugl-Meyer AR, Lodnert G, Branholm IB, et al. On life satisfaction in male erectile dysfunction. Int J Impot Res. 1997;9(3):141-148. [pmid: 9315491].
Godschalk M, Gheorghiu D, Chen J, et al. Long-term efficacy of a new formulation of prostaglandin E1 as treatment for erectile failure. Br J Urol. 1996;155(3):915-917.
Govier FE, McClure RD, Weissman RM, et al. Experience with triple-drug therapy in a pharmacological erection program.[see comment]. Br J Urol. 1993;150(6):1822-1824.
Incrocci L, Hop WC, Slob AK. Visual erotic and vibrotactile stimulation and intracavernous injection in screening men with erectile dysfunction: a 3 year experience with 406 cases. Int J Impot Res. 1996;8(4):227-232. [pmid: 8981172].
Irwin MB, Kata EJ. High attrition rate with intracavernous injection of prostaglandin E1 for impotency. Urology. 1994;43(1):84-87. [pmid: 8284888].
Jiann BP, Yu CC, Su CC. Impact of introduction of sildenafil on other treatment modalities for erectile dysfunction: A study of nationwide and local hospital sales. Int J Impot Res. 2004;16(6):527-530. [pmid: 15229626].
Kattan SA. The acceptance of satisfaction of Saudi males to vasoactive autoinjection intracavernous therapy, external negative pressure device and penile prosthesis in the treatment of erectile dysfunction. Ann Saudi Med. 2002;22(34):149-152. [pmid: 17159384].
Knispel HH, Huland H. Influence of cause on choice of therapy in 174 patients with erectile dysfunction. Br J Urol. 1992;147(5):1274-1276.
Lim PH, Ng FC. Erectile dysfunction in Singapore men: presentation, diagnosis, treatment and results. Ann Acad Med Singapore. 1992;21(2):248-253. [pmid: 1519896].
Lottman PE, Hendriks JC, Vruggink PA, et al. The impact of marital satisfaction and psychological counselling on the outcome of ICI-treatment in men with ED. Int J Impot Res. 1998;10(2):83-87. [pmid: 9647943].
Lundberg L, Olsson JO, Kihl B. Long-term experience of self-injection therapy with prostaglandin E1 for erectile dysfunction. Scand J Urol Nephrol. 1996;30(5):395-397. [pmid: 8936629].
Maniam P, Seftel AD, Corty EW, et al. Nocturnal penile tumescence activity unchanged after long-term intracavernous injection therapy. Br J Urol. 2001;165(3):830-832.
Mark SD, Keane TE, Vandemark RM, et al. Impotence following pelvic fracture urethral injury: incidence, aetiology and management. Br J Urol. 1995;75(1):62-64. [pmid: 7850299].
Montorsi F, Guazzoni G, Bergamaschi F, et al. Effectiveness and safety of multidrug intracavernous therapy for vasculogenic impotence. Urology. 1993;42(5):554-558. [pmid: 7694416].
Montorsi F, Guazzoni G, Bergamaschi F, et al. Four-drug intracavernous therapy for impotence due to corporeal veno-occlusive dysfunction. Br J Urol. 1993;149(5 Pt 2):1291-1295.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Intracavernous vasoactive pharmacotherapy: the impact of a new self-injection device.[see comment]. Br J Urol. 1993;150(6):1829-1832.
Mulhall JP, Jahoda AE, Cairney M, et al. The causes of patient dropout from penile self-injection therapy for impotence. Br J Urol. 1999;162(4):1291-1294.
Mulhall JP, Land S, Parker M, et al. The use of an erectogenic pharmacotheraphy regimen following radical prostatectomy improves recovery of spontaneous erectile function. Br J Sex Med. 2005;2(4):532-542.
Perimenis P, Athanasopoulos A, Geramoutsos I, et al. The incidence of pharmacologically induced priapism in the diagnostic and therapeutic management of 685 men with erectile dysfunction. Urol Int. 2001;66(1):27-29. [pmid: 11150947].
Rowland DL, Boedhoe HSM, Dohle G, et al. Intracavernosal self-injection therapy in men with erectile dysfunction: Satisfaction and attrition in 119 patients. Int J Impot Res. 1999;11(3):145-151. [pmid: 10404283].
Sparwasser C, Treiber U, Bahren W, et al. Postoperative erectile dysfunction; evaluation and treatment with intracavernous vasoactive injections. Progress in Clinical & Biological Research. 1991;370:349-354. [pmid: 1924468].
Speckens AE, Kattemolle MR, Hengeveld MW, et al. A prospective long-term follow-up study of patients evaluated for erectile dysfunction: outcome and associated factors. Int J Impot Res. 1995;7(2):101-110. [pmid: 7496438].
Tariq SH, Haleem U, Omran ML, et al. Erectile dysfunction: Etiology and treatment in young and old patients. Clin Geriatr Med. 2003;19(3):539-551. [pmid: 14567006].
Turner LA, Althof SE. The clinical effectiveness of self-injection and external vacuum devices in the treatment of erectile dysfunction: a six-month comparison. Psychiatr Med. 1992;10(2):283-293. [pmid: 1377397].
Virag R. Intracavernous injection of papaverine for erectile failure. 1982. Br J Urol. 2002;167(2 Pt 2):1196.
Weidner W, Schroeder-Printzen I, Fischer C, et al. Experience in the treatment of erectile dysfunction using the intracavernosal self-injection of papaverine: Results of a prospective study after a median follow-up of 42 months involving 135 patients and 10766 injections. World J Urol. 1992;10(3):179-182.
Weiss JN, Badlani GH, Ravalli R, et al. Reasons for high drop-out rate with self-injection therapy for impotence. Int J Impot Res. 1994;6(3):171-174. [pmid: 7735362].

## Not relevant by study design

Allan CA, McLachlan RI. Age-related changes in testosterone and the role of replacement therapy in older men. Clin Endocrinol (Oxf). 2004;60(6):653-670. [pmid: 15163327].
Anderson DC, Seifert CF. Topical nitrate treatment of impotence. [Review] [17 refs]. Ann Pharmacother. 1993;27(10):1203-1205. [pmid: 8251690].
Anonymous. Sildenafil for erectile dysfunction. Drug Ther.Bull 1998;36(11):81–84.
Anonymous. Vardenafil (levitra) for erectile dysfunction. Medical Letter on Drugs & Therapeutics 2003;45(1166):77–78.
Anonymous. Vasoactive intestinal peptide/phentolamine. Invicorp, vasopotin. Drugs in R & D 1999;2(6):436–438.
Berner M M, Kriston L, Harms A. Efficacy of PDE-5-inhibitors for erectile dysfunction. A comparative meta-analysis of fixed-dose regimen randomized controlled trials administering the International Index of Erectile Function in broad-spectrum populations. Int J Impot Res 2005;
Blanker MH, Thomas S, Bohnen AM. Systematic review of Viagra RCTs. Br J Gen Pract. 2002;52(477):329. [pmid: 11942454].
Bolona ER, Uraga MV, Haddad RM, et al. Testosterone use in men with sexual dysfunction: a systematic review and meta-analysis of randomized placebo-controlled trials. Mayo Clin Proc. 2007;82(1):20-28. [pmid: 17285782].
Burls A, Gold L, Clark W. Systematic review of randomised controlled trials of sildenafil (Viagra) in the treatment of male erectile dysfunction. Br J Gen Pract. 2001;51(473):1004-1012. [pmid: 11766850].
Calof OM, Singh AB, Lee ML, et al. Adverse events associated with testosterone replacement in middle-aged and older men: A meta-analysis of randomized, placebo-controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60(11):1451-1457.
Carey MP, Johnson BT. Effectiveness of yohimbine in the treatment of erectile disorder: four meta-analytic integrations. Arch Sex Behav. 1996;25(4):341-360. [pmid: 8836468].
Carson CC, Burnett AL, Levine LA, et al. The efficacy of sildenafil citrate (Viagra) in clinical populations: an update. Urology. 2002;60(2 Suppl 2):12-27. [pmid: 12414330].
Chen CT, Valicenti RK, Lu J, et al. Does hormonal therapy influence sexual function in men receiving 3D conformal radiation therapy for prostate cancer?. Int J Radiat Oncol Biol Phys. 2001;50(3):591-595. [pmid: 11395224].
Chiang HS, Kao YH, Sheu MT. Papaverine and prostaglandin E1 gel applications for impotence. Ann Acad Med Singapore. 1995;24(5):767-769. [pmid: 8579329].
Crowe SM, Streetman DS. Vardenafil treatment for erectile dysfunction. [Review] [43 refs]. Ann Pharmacother. 2004;38(1):77-85. [pmid: 14742800].
Derry F, Hultling C, Seftel AD, et al. Efficacy and safety of sildenafil citrate (Viagra) in men with erectile dysfunction and spinal cord injury: a review. Urology. 2002;60(2 Suppl 2):49-57. [pmid: 12414333].
Ernst E, Pittler MH. Yohimbine for erectile dysfunction: a systematic review and meta-analysis of randomized clinical trials. J Urol. 1998;159(2):433-436. [pmid: 9649257].
Escobar-Jimenez F. [Efficacy and safety of sildenafil in men with type 2 diabetes mellitus and erectile dysfunction]. Med Clin (Barc). 2002;119(4):121-124. [pmid: 12106522].
Fink HA, Mac Donald R, Rutks IR, et al. Sildenafil for male erectile dysfunction: a systematic review and meta-analysis. Arch Intern Med. 2002;162(12):1349-1360. [pmid: 12076233].
Fink HA, MacDonald R, Rutks IR, et al. Trazodone for erectile dysfunction: a systematic review and meta-analysis. BJU Int. 2003;92(4):441-446. [pmid: 12930437].
Hellstrom WJ. Vardenafil: a new approach to the treatment of erectile dysfunction. [Review] [37 refs]. Curr Urol Rep. 2003;4(6):479-487. [pmid: 14622502].
Holmes S. Tadalafil: a new treatment for erectile dysfunction. BJU Int. 2003;91(6):466-468. [pmid: 12656894].
Isidori AM, Giannetta E, Gianfrilli D, et al. Effects of testosterone on sexual function in men: results of a meta-analysis. Clin Endocrinol (Oxf). 2005;63(4):381-394. [pmid: 16181230].
Jain P, Rademaker AW, McVary KT. Testosterone supplementation for erectile dysfunction: results of a meta-analysis. Br J Urol. 2000;164(2):371-375.
Keating GM, Scott LJ. Vardenafil: a review of its use in erectile dysfunction. Drugs. 2003;63(23):2673-2703. [pmid: 14636086].
Keating GM, Scott LJ. Spotlight on vardenafil in erectile dysfunction. Drugs Aging. 2004;21(2):135-140. [pmid: 14960129].
Kloner RA. Cardiovascular effects of the 3 phosphodiesterase-5 inhibitors approved for the treatment of erectile dysfunction. [Review] [57 refs]. Circulation. 2004;110(19):3149-3155. [pmid: 15533876].
Langtry HD, Markham A. Sildenafil: a review of its use in erectile dysfunction. Drugs. 1999;57(6):967-989. [pmid: 10400408].
Lewis RW. Intraurethral and topical agents. Med Actual. 2000;36(23):113-119.
Licht M R, Schover L R. Sildenafil (Viagra) for treating male erectile dysfunction. Cleve Clin J Med 1998;65(6):
Markou S, Perimenis P, Gyftopoulos K, et al. Vardenafil (Levitra) for erectile dysfunction: a systematic review and meta-analysis of clinical trial reports. Int J Impot Res. 2004;16(6):470-478. [pmid: 15229625].
McMahon CG. Topiglan: MacroChem. Curr Opin Investig Drugs. 2002;3(4):602-606.
Mikhail N. Does Testosterone Have a Role in Erectile Function?. Am J Med. 2006;119:373-382. [pmid: 16651047].
Montorsi F, McCullough A. Efficacy of sildenafil citrate in men with erectile dysfunction following radical prostatectomy: A systematic review of clinical data. Br J Sex Med. 2005;2(5):658-667.
Moore R A, Derry S, McQuay H J. Indirect comparison of interventions using published randomised trials: systematic review of PDE-5 inhibitors for erectile dysfunction. [Review][77 refs]. BMC Urol 2005;518
Moore R A, Edwards J E, McQuay H J. Sildenafil (Viagra) for male erectile dysfunction: a meta-analysis of clinical trial reports. BMC Urol. 2002;26
Morales A, Gingell C, Collins M, et al. Clinical safety of oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):69-73. [pmid: 9647940].
Padma-Nathan H, Eardley I, Kloner R A et al. A 4-year update on the safety of sildenafil citrate (Viagra). [Review][88 refs]. Urology 2002;60(2:Suppl 2):Suppl-90.
Rashid A. The efficacy and safety of PDE5 inhibitors. [Review] [30 refs]. Clin Cornerstone. 2005;7(1):47-56. [pmid: 16156423].
Rudkin L, Taylor M J, Hawton K. Strategies for managing sexual dysfunction induced by antidepressant medication. [Review][61 refs]. Cochrane Database Syst Rev 2004;(4):CD003382
Setter SM, Iltz JL, Fincham JE, et al. Phosphodiesterase 5 inhibitors for erectile dysfunction. [Review] [75 refs]. Ann Pharmacother. 2005;39(78):1286-1295. [pmid: 15941818].
Sommer F, Engelmann U. Vardenafil: Bayer Yakuhin. Curr Opin Investig Drugs. 2002;3(4):607-613.
Sternbach Harvey. Age-associated testosterone decline in men: Clinical issues for psychiatry. Am J Psychiatry. 1998;155(10):1310-1318. [pmid: 9766760].
Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005;88(3):241-254. [pmid: 16162361].
Tomsak R. PDE5 inhibitors and permanent visual loss. Int J Impot Res. 2005;17(6):547-549. [pmid: 16193072].
Tran D, Howes LG. Cardiovascular safety of sildenafil. Drug Saf. 2003;26(7):453-460. [pmid: 12735784].
Urciuoli R, Cantisani T A, CarliniI M et al. Prostaglandin E1 for treatment of erectile dysfunction. Cochrane Database Syst Rev 2004;(2):CD001784

## Not an original study, or population of interest, intervention of interest, or outcome of interest

Abdallah HM. Comparison of Alprostadil (Caverject) and a combination of vasoactive drugs as local injections for the treatment of erectile dysfunction. Int Urol Nephrol. 1998;30(5):617-620. [pmid: 9934808].
Abrams J. Time course of the interaction between tadalafil and nitrates.[comment]. J Am Coll Cardiol. 2004;43(11):2150-2151. [pmid: 15172433].
Adaikan PG, Chong YS, Chew SSL, et al. Male sexual dysfunction. Curr Obstet Gynaecol. 2000;10(1):23-28.
Adams MA, Perdok RJ, Padley RJ, et al. Safety and tolerability of apomorphine SL in men with cardiovascular disorders. European Urology Supplements. 2002;1(3):28-32.
Agelink MW, Schmitz T, Rembrink K, et al. Cardiovascular effects of sildenafil citrate (Viagra): a naturalistic cross-over study. Eur J Med Res. 2001;6(11):459-464. [pmid: 11726304].
Ahuja SK, Krane NK, Hellstrom WJ. Penile prostheses in the management of impotence in patients with end-stage renal disease. J La State Med Soc. 1998;150(1):32-34. [pmid: 9448384].
Aizenberg Dov, Gur Shay, Zemishlany Zvi, et al. Mianserin, a 5-HT-sub(2a/2c) and alpha -sub-2 antagonist, in the treatment of sexual dysfunction induced by serotonin reuptake inhibitors. Clin Neuropharmacol. 1997;20(3):210-214. [pmid: 9197943].
Aizenberg Dov, Weizman Abraham, Barak Yoram, et al. Sildenafil for selective serotonin reuptake inhibitor-induced erectile dysfunction in elderly male depressed patients. [References]. J Sex Marital Ther. 2003;29(4):297-303. [pmid: 14504018].
al-Juburi AZ, O'Donnell PD. Follow up outcome of intracavernous papaverine. J Ark Med Soc. 1990;86(10):383-385. [pmid: 2138146].
Alivizatos G, Skolarikos A, Laguna P. Recent data upon impotence, incontinence and quality of life issues concerning radical prostatectomy. [Review] [74 refs]. Arch Esp Urol. 2003;56(3):321-330. [pmid: 12768997].
Allan CA, McLachlan RI. Age-related changes in testosterone and the role of replacement therapy in older men. Clin Endocrinol (Oxf). 2004;60(6):653-670. [pmid: 15163327].
Althof SE, Cappelleri JC, Shpilsky A, et al. Treatment responsiveness of the Self-Esteem And Relationship questionnaire in erectile dysfunction. Urology. 2003;61(5):888-892. [pmid: 12735997].
Althof SE, O'Leary MP, Cappelleri JC, et al. Self-esteem, confidence, and relationships in men treated with sildenafil citrate for erectile dysfunction: results of two double-blind, placebo-controlled trials. J Gen Intern Med. 2006;21(10):1069-1074. [pmid: 16836626].
Altwein JE, Keuler FU. Oral treatment of erectile dysfunction with apomorphine SL. [Review] [34 refs]. Urol Int. 2001;67(4):257-263. [pmid: 11741126].
Anderson DC, Seifert CF. Topical nitrate treatment of impotence. [Review] [17 refs]. Ann Pharmacother. 1993;27(10):1203-1205. [pmid: 8251690].
Anderson RA, Bancroft J, Wu FC. The effects of exogenous testosterone on sexuality and mood of normal men. Journal of Clinical Endocrinology & Metabolism. 1992;75(6):1503-1507. [pmid: 1464655].
Andersson KE. Pharmacology of penile erection. Pharmacol Rev. 2001;53(3):417-450. [pmid: 11546836].
Anonymous. Sildenafil and erectile dysfunction: new preparation. Helpful. Prescrire.Int 1998;7(38):163–165.
Anonymous. Sublingual apomorphine: new preparation. In erectile disorders: a narrow therapeutic margin. Prescrire.Int 2002;11(59):76–79.
Anonymous. Vardenafil (levitra) for erectile dysfunction. Medical Letter on Drugs &Therapeutics 2003;45(1166):77–78.
Anonymous. Viagra: a blueprint for safety and reliability. Johns Hopkins Medical Letter, Health After 50 2002;14(10):4–5.
Anonymous. Vasoactive intestinal peptide/phentolamine. Invicorp, vasopotin. Drugs in R &D 1999;2(6):436–438.
Anonymous. Treatment for impotence gains FDA approval. Am J Health Syst Pharm 1995;52(19):2078–2079.
Anonymous. L-arginine. Altern Med Rev 2005;10(2):139–147.
Anonymous. Use of sildenafil for ED classes II and III. S Afr Med J 2005;95(1):38
Anonymous. Patient preference of ED drugs studied. British Journal of Diabetes &Vascular Disease 2003;3(6):444
Anonymous. New drug for erectile dysfunction. Can Pharm J 2002;268(7200):756
Anonymous. Vardenafil improves erectile function in men with diabetes. Can Pharm J 2001;267(7155):
Anonymous. Alprostadil for erectile impotence. Drug &Therapeutics Bulletin 1995;33(8):61–62.
Anonymous. What to do if Viagra won't do. Harvard Mens Health Watch 2005;9(10):4–8.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: intracavernous injection of prostaglandin E1. JAMA 1991;265(24):3321–3323.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: papaverine and phentolamine. JAMA 1990;264(6):752–754.
Aranda P, Ruilope LM, Calvo C, et al. Erectile dysfunction in essential arterial hypertension and effects of sildenafil: results of a Spanish national study. Am J Hypertens. 2004;17(2):139-145. [pmid: 14751656].
Ardicoglu A, Kocakoc E, Tuygun UO, et al. Effectiveness of vardenafil versus papaverine in penile Doppler ultrasonography. Urol Int. 2005;75(1):75-79. [pmid: 16037713].
Ardicoglu A, Kocakoc E, Yuzgec V, et al. Hemodynamic effects of sildenafil citrate (Viagra) on segmental branches of bilateral renal arteries. International Urology & Nephrology. 2005;37(4):785-789. [pmid: 16362600].
Armstrong DK, Convery AG, Dinsmore WW. Reasons for patient drop-out from an intracavernous auto-injection programme for erectile dysfunction. Br J Urol. 1994;74(1):99-101. [pmid: 8044533].
Armstrong DK, Convery A, Dinsmore WW. Prostaglandin E1 in the medical management of erectile dysfunction in a genito-urinary medicine clinic. Ulster Med J. 1994;63(1):18-22. [pmid: 8658990].
Arver S, Dobs AS, Meikle AW, et al. Improvement of sexual function in testosterone deficient men treated for 1 year with a permeation enhanced testosterone transdermal system. Br J Urol. 1996;155(5):1604-1608.
Ashok S, Sigman M. Bioavailable testosterone should be used for the determination of androgen levels in infertile men. Br J Urol. 2007;177(4):1443-1446.
Ashton Adam, Keller. Yohimbine in the treatment of male erectile dysfunction. Am J Psychiatry. 1994;151(9):1397. [pmid: 8067505].
Assalian Pierre. Sildenafil for St. John wort-induced sexual dysfunction. [References]. J Sex Marital Ther. 2000;26(4):357-358. [pmid: 11056902].
Atmaca M, Kuloglu M, Tezcan E. Sildenafil use in patients with olanzapine-induced erectile dysfunction. Int J Impot Res. 2002;14(6):547-549. [pmid: 12494295].
Aukst-Margetic B, Margetic B. An open-label series using loratadine for the treatment of sexual dysfunction associated with selective serotonin reuptake inhibitors. Prog Neuropsychopharmacol Biol Psychiatry. 2005;29(5):754-756. [pmid: 15913872].
Aversa A, Bonifacio V, Moretti C, et al. Re-dosing of prostaglandin-E1 versus prostaglandin-E1 plus phentolamine in male erectile dysfunction: a dynamic color power Doppler study. Int J Impot Res. 2000;12(1):33-40. [pmid: 10982310].
Aviv A, Shelef A, Weizman A. An open-label trial of sildenafil addition in risperidone-treated male schizophrenia patients with erectile dysfunction. Hillside J Clin Psychiatry. 2004;65(1):97-103.
Ayub W, Fletcher S. End-stage renal disease and erectile dysfunction. Is there any hope?. Nephrology Dialysis Transplantation. 2000;15(10):1525-1528.
Bacar MM, Batislam E, Altinok D, et al. Sildenafil citrate for penile hemodynamic determination: an alternative to intracavernosal agents in Doppler ultrasound evaluation of erectile dysfunction. Urology. 2001;57(4):623-626. [pmid: 11306361].
Bach Amy K, Barlow David H, Wincze John PE. The enhancing effects of manualized treatment for erectile dysfunction among men using sildenafil: A preliminary investigation. [References]. Behav Ther. 2004;35(1):55-73.
Bai WJ, Zhu JC, Jiang H, et al. [A comparative study of different vasoactive drugs in the treatment of impotence]. Chinese Journal of Urology. 1992;13(6):453-455.
Bain J. Andropause. Testosterone replacement therapy for aging men. [Review] [55 refs]. Can Fam Physician. 2001;47:91-97. [pmid: 11212438].
Balon Richard. Sildenafil and sexual dysfunction associated with antidepressants. [References]. J Sex Marital Ther. 1999;25(4):259-264. [pmid: 10546162].
Balon Richard. Fluvoxamine-induced erectile dysfunction responding to sildenafil. J Sex Marital Ther. 1998;24(4):313-317. [pmid: 9805292].
Bancroft J, Gutierrez P. Erectile dysfunction in men with and without diabetes mellitus: a comparative study.[see comment]. Diabet Med. 1996;13(1):84-89. [pmid: 8741818].
Bancroft J, Smith G, Munoz M, et al. Erectile response to visual erotic stimuli before and after intracavernosal papaverine, and its relationship to nocturnal penile tumescence and psychometric assessment. Br J Urol. 1991;68(6):629-638. [pmid: 1773296].
Baniel J, Israilov S, Engelstein D, et al. Three-year outcome of a progressive treatment program for erectile dysfunction with intracavernous injections of vasoactive drugs. Urology. 2000;56(4):647-652. [pmid: 11018623].
Barrou B, Cuzin B, Malavaud B, et al. Early experience with sildenafil for the treatment of erectile dysfunction in renal transplant recipients. Nephrol.Dial.Transplant. 2003;18(2):411-417. [pmid: 12543900].
Beal K, Mears JG. Short report: Penile lymphoma following local injections for erectile dysfunction. Leuk Lymphoma. 2001;42(12):247-249. [pmid: 11699217].
Becher E. Topical alprostadil cream for the treatment of erectile dysfunction. [Review] [46 refs]. Expert Opin Pharmacother. 2004;5(3):623-632. [pmid: 15013930].
Behrend L, Vibe-Petersen J, Perrild H. Sildenafil in the treatment of erectile dysfunction in men with diabetes: demand, efficacy and patient satisfaction. Int J Impot Res. 2005;17(3):264-269. [pmid: 15674401].
Bell DSH, Cutter GR, Hayne VB, et al. Factors predicting efficacy of phentolamine-papaverine intracorporeal injection for treatment of erectile dysfunction in diabetic male. Urology. 1992;40(1):36-40. [pmid: 1621310].
Benatov R, Reznik I, Zemishlany Z. Sildenafil citrate (Viagra) treatment of sexual dysfunction in a schizophrenic patient. [References]. Eur Psychiatry. 1999;14(6):353-355. [pmid: 10572370].
Benchekroun A, Faik M, Benjelloun S, et al. A baseline-controlled, open-label, flexible dose-escalation study to assess the safety and efficacy of sildenafil citrate (Viagra) in patients with erectile dysfunction. Int J Impot Res. 2003;15(Suppl 1):19-24.
Benevides MD, Carson CC. Intraurethral application of alprostadil in patients with failed inflatable penile prosthesis. Br J Urol. 2000;163(3):785-787.
Beretta G, Marzotto M, Zanollo A, et al. Office treatment: intracavernous injections of prostaglandin E1 (PG E1) and improvement of spontaneous erections. Acta Eur Fertil. 1991;22(4):221-223. [pmid: 1844326].
Berner M M, Kriston L, Harms A. Efficacy of PDE-5-inhibitors for erectile dysfunction. A comparative meta-analysis of fixed-dose regimen randomized controlled trials administering the International Index of Erectile Function in broad-spectrum populations. Int J Impot Res 2005;
Billington CJ, Shafer RB, Morley JE. Effects of opioid blockade with nalmefene in older impotent men. Life Sci. 1990;47(9):799-805. [pmid: 2120527].
Bird TD, Lipe HP, Crabtree LD. Impotence associated with the Charcot-Marie-Tooth syndrome. Eur Neurol. 1994;34(3):155-157. [pmid: 8033941].
Bischoff E. Vardenafil preclinical trial data: Potency, pharmacodynamics, pharmacokinetics, and adverse events. Int J Impot Res. 2004;16(SUPPL. 1):S34-S37. [pmid: 15224134].
Black AM, Day AG, Morales A. The reliability of clinical and biochemical assessment in symptomatic late-onset hypogonadism: Can a case be made for a 3-month therapeutic trial?. BJU Int. 2004;94(7):1066-1070. [pmid: 15541129].
Blanker MH, Thomas S, Bohnen AM. Systematic review of Viagra RCTs. Br J Gen Pract. 2002;52(477):329. [pmid: 11942454].
Blonde L. Sildenafil citrate for erectile dysfunction in men with diabetes and cardiovascular risk factors: a retrospective analysis of pooled data from placebo-controlled trials. Curr Med Res Opin. 2006;22(11):2111-2120. [pmid: 17076971].
Bocchi EA, Guimaraes G, Mocelin A, et al. Sildenafil effects on exercise, neurohormonal activation, and erectile dysfunction in congestive heart failure: a double-blind, placebo-controlled, randomized study followed by a prospective treatment for erectile dysfunction. Circulation. 2002;106(9):1097-1103. [pmid: 12196335].
Bodansky HJE. Successful tadalafil treatment for erectile dysfunction associated with Charcot-Marie-Tooth syndrome. [References]. Sexual and Relationship Therapy. 2006;21(1):87-89.
Bolona ER, Uraga MV, Haddad RM, et al. Testosterone use in men with sexual dysfunction: a systematic review and meta-analysis of randomized placebo-controlled trials. Mayo Clin Proc. 2007;82(1):20-28. [pmid: 17285782].
Bouloux P. Testim 1% testosterone gel for the treatment of male hypogonadism. [Review] [33 refs]. Clin Ther. 2005;27(3):286-298. [pmid: 15878382].
Boyarsky BK, Haque W, Rouleau MR, et al. Sexual functioning in depressed outpatients taking mirtazapine. Depression & Anxiety. 1999;9(4):175-179. [pmid: 10431683].
Braatvedt GD. Outcome of managing impotence in clinical practice. N Z Med J. 1999;112(1092):272-274. [pmid: 10472891].
Brazil M. Viagra for broken hearts?. Nat Rev Genet. 2005;4(3):190.
Briganti A, Salonia A, Gallina A, et al. Drug insight: Oral phosphodiesterase type 5 inhibitors for erectile dysfunction. Nature Clinical Practice Urology. 2005;2(5):239-247.
Brignardello E, Manti R, Papotti M, et al. Ectopic secretion of LH by an endocrine pancreatic tumor. J Endocrinol Invest. 2004;27(4):361-365. [pmid: 15233557].
Brindis RG, Kloner RA. Sildenafil in patients with cardiovascular disease. [Review] [33 refs]. Am J Cardiol. 2003;92(9A):26M-36M. [pmid: 12842240].
Brisson TE, Broderick GA, Thiel DD, et al. Vardenafil rescue rates of sildenafil nonresponders: objective assessment of 327 patients with erectile dysfunction. Urology. 2006;68(2):397-401. [pmid: 16904460].
Brock GB, McMahon CG, Chen KK, et al. Efficacy and safety of tadalafil for the treatment of erectile dysfunction: results of integrated analyses. Br J Urol. 2002;168(4 Pt 1):1332-1336.
Brock G, Chan J, Carrier S, et al. The treatment of erectile dysfunction study: focus on treatment satisfaction of patients and partners. BJU Int. 2007;99(2):376-382. [pmid: 17155989].
Brown SL, Haas CA, Koehler M, et al. Hepatotoxicity related to intracavernous pharmacotherapy with papaverine. Urology. 1998;52(5):844-847. [pmid: 9801111].
Buddeberg C, Bucher T, Hornung R. [Erectile dysfunction in men in their second half of life]. Urologe 2005;Ausg. A. 44(9):1045–1046, 1048–51.
Burge MR, Lanzi RA, Skarda ST, et al. Idiopathic hypogonadotropic hypogonadism in a male runner is reversed by clomiphene citrate. Fertility & Sterility. 1997;67(4):783-785. [pmid: 9093212].
Burls A, Gold L, Clark W. Systematic review of randomised controlled trials of sildenafil (Viagra) in the treatment of male erectile dysfunction. Br J Gen Pract. 2001;51(473):1004-1012. [pmid: 11766850].
Burnett AL. Vasoactive pharmacotherapy to cure erectile dysfunction: fact or fiction?. [Review] [45 refs]. Urology. 2005;65(2):224-230. [pmid: 15708027].
Burns-Cox N, Gingell C. The andropause: fact or fiction?. [Review] [49 refs]. Postgrad Med J. 1997;73(863):553-556. [pmid: 9373594].
Buvat J. Hyperprolactinemia and sexual function in men: a short review. [Review] [26 refs]. Int J Impot Res. 2003;15(5):373-377. [pmid: 14562140].
Buvat J, Montorsi F. Safety and tolerability of apomorphine SL in patients with erectile dysfunction. BJU Int. 2001;88(3):30-35. [pmid: 11578277].
Buvat J, Lemaire A, Ratajczyk J. Acceptance, efficacy and preference of Sildenafil in patients on long term auto-intracavernosal therapy: a study with follow-up at one year. Int J Impot Res. 2002;14(6):483-486. [pmid: 12494282].
Calof OM, Singh AB, Lee ML, et al. Adverse events associated with testosterone replacement in middle-aged and older men: A meta-analysis of randomized, placebo-controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60(11):1451-1457.
Cappelleri JC, Althof SE, Siegel RL, et al. Association between the Erectile Dysfunction Inventory of Treatment Satisfaction and the Self-Esteem and Relationship Questionnaire following treatment with sildenafil citrate for men with erectile dysfunction. Value Health. 2005;8(Suppl 1):54-60.
Cappelleri JC, Bell SS, Althof SE, et al. Comparison between sildenafil-treated subjects with erectile dysfunction and control subjects on the Self-Esteem And Relationship questionnaire. Br J Sex Med. 2006;3(2):274-282.
Carani C, Granata AR, Bancroft J, et al. The effects of testosterone replacement on nocturnal penile tumescence and rigidity and erectile response to visual erotic stimuli in hypogonadal men. Psychoneuroendocrinology. 1995;20(7):743-753. [pmid: 8848520].
Carani C, Zini D, Baldini A, et al. Effects of androgen treatment in impotent men with normal and low levels of free testosterone. Arch Sex Behav. 1990;19(3):223-234. [pmid: 2193636].
Caretta N, Palego P, Ferlin A, et al. Resumption of spontaneous erections in selected patients affected by erectile dysfunction and various degrees of carotid wall alteration: Role of tadalafil. Eur Urol. 2005;48(2):326-332. [pmid: 16005378].
Carey F, Quah SP, Dinsmore W. Postal survey to determine how many patients continued to seek treatment with sildenafil following sildenafil trials. Int J STD AIDS. 2003;14(7):501-502. [pmid: 12869236].
Carey MP, Johnson BT. Effectiveness of yohimbine in the treatment of erectile disorder: four meta-analytic integrations. Arch Sex Behav. 1996;25(4):341-360. [pmid: 8836468].
Carosa E, Martini P, Brandetti F, et al. Type V phosphodiesterase inhibitor treatments for erectile dysfunction increase testosterone levels. Clin Endocrinol (Oxf). 2004;61(3):382-386. [pmid: 15355456].
Carson CC, Burnett AL, Levine LA, et al. The efficacy of sildenafil citrate (Viagra) in clinical populations: an update. Urology. 2002;60(2 Suppl 2):12-27. [pmid: 12414330].
Carson CC, Rajfer J, Eardley I, et al. The efficacy and safety of tadalafil: an update. BJU Int. 2004;93(9):1276-1281. [pmid: 15180622].
Caruso S, Intelisano G, Farina M, et al. Efficacy and safety of daily intake of apomorphine SL in men affected by erectile dysfunction and mild hyperprolactinemia: a prospective, open-label, pilot study. Urology. 2003;62(5):922-927. [pmid: 14624921].
Casella R, Deckart A, Bachmann A, et al. The patient's self-evaluation better predicts the degree of erectile dysfunction than the response to intracavernous alprostadil testing. Urol Int. 2004;72(3):216-220. [pmid: 15084765].
Chaiban JT, Azar ST. Erectile dysfunction in diabetic patients. J Med Liban. 2004;52(4):217-219. [pmid: 16432985].
Chatterjee R, Kottaridis PD, McGarrigle HH, et al. Management of erectile dysfunction by combination therapy with testosterone and sildenafil in recipients of high-dose therapy for haematological malignancies. Bone Marrow Transplant. 2002;29(7):607-610. [pmid: 11979311].
Cheitlin MD, Hutter AM, Brindis RG, et al. Use of sildenafil (Viagra) in patients with cardiovascular disease. Circulation. 1999;99(1):168-177. [pmid: 9884398].
Chen JK, Hwang TI, Yang CR. Comparison of effects following the intracorporeal injection of papaverine and prostaglandin E1. Br J Urol. 1992;69(4):404-407. [pmid: 1581812].
Chen J, Godschalk MF, Katz PG, et al. Incidence of penile pain after injection of a new formulation of prostaglandin E1.[see comment]. Br J Urol. 1995;154(1):77-79.
Chen J, Godschalk MF, Katz PG, et al. Combining intracavernous injection and external vacuum as treatment for erectile dysfunction.[see comment]. Br J Urol. 1995;153(5):1476-1477.
Chen J, Godschalk M, Katz PG, et al. The lowest effective dose of prostaglandin E1 as treatment for erectile dysfunction. Br J Urol. 1995;153(1):80-81.
Chen J, Mabjeesh NJ, Greenstein A, et al. Clinical efficacy of sildenafil in patients on chronic dialysis. Br J Urol. 2001;165(3):819-821.
Chen J, Sofer M, Kaver I, et al. Concomitant use of sildenafil and a vacuum entrapment device for the treatment of erectile dysfunction. Br J Urol. 2004;171(1):292-295.
Chen KK, Jiann BP, Lin JSN, et al. Erratum: Efficacy and safety of on- demand oral tadalafil in the treatment of men eith erectile dysfunction in Taiwan: A randomized, double- blind, parallel, placebo- conrolled clinical study (Journal of Sexual Medicine vol. 1 (2)). Br J Sex Med. 2005;2(1):158.
Cheng E. Real-life safety and efficacy of vardenafil in the treatment of erectile dysfunction-results from 30,010 U.S. patients. Br J Sex Med. 2007;4(2):432-439.
Chew KK. Prevalence of hypogonadism in the aging male and male erectile dysfunction in Asia-Pacific countries. Asian J Androl. 2003;5(2):171-172.
Chew KK, Stuckey BGA. Use of transurethral alprostadil (MUSE) (prostaglandin E1) for glans tumescence in a patient with penile prosthesis. Int J Impot Res. 2000;12(3):195-196. [pmid: 11045915].
Chew KK, Stuckey BGA, Thompson PL. Erectile dysfunction, sildenafil and cardiovascular risk. Med J Aust. 2000;172(6):279-283. [pmid: 10860094].
Chia S. Management of premature ejaculation—a comparison of treatment outcome in patients with and without erectile dysfunction. Int J Androl. 2002;25(5):301-305. [pmid: 12270028].
Chia SJ, Ramesh K, Earnest A. Clinical application of prognostic factors for patients with organic causes of erectile dysfunction on 100 mg of sildenafil citrate. Int J Urol. 2004;11(12):1104-1109. [pmid: 15663683].
Chiang HS, Wen TC, Liang JF. Titration study of MUSE (Medicated Urethral System for Erection) in erectile dysfunction. J Formos Med Assoc. 2000;99(12):926-930. [pmid: 11155746].
Chiang HS, Kao YH, Sheu MT. Papaverine and prostaglandin E1 gel applications for impotence. Ann Acad Med Singapore. 1995;24(5):767-769. [pmid: 8579329].
Chiang PH, Tsai EM, Chiang CP. The role of trazodone in the treatment of erectile dysfunction. Kao-Hsiung i Hsueh Ko Hsueh Tsa Chih [Kaohsiung Journal of Medical Sciences]. 1994;10(6):287-294.
Chinegwundoh F, Anie K A. Treatments for priapism in boys and men with sickle cell disease. [Review][16 refs]. Cochrane Database Syst Rev 2004;(4):CD004198
Choi HK, Adimoelja A, Kim SC, et al. A dose-response study of alprostadil sterile powder (S.Po.) (Caverject) for the treatment of erectile dysfunction in Korean and Indonesian men. Int J Impot Res. 1997;9(1):47-51. [pmid: 9138059].
Christ B, Brockmeier D, Hauck EW, et al. Investigation on interaction between tacrolimus and sildenafil in kidney-transplanted patients with erectile dysfunction. International Journal of Clinical Pharmacology & Therapeutics. 2004;42(3):149-156. [pmid: 15049434].
Christ GJ, Melman A. The application of gene therapy to the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):111-112. [pmid: 9647947].
Chun SS, Fenemore J, Heaton JP, et al. Enhancement of erectile responses to vasoactive drugs by a variable amplitude oscillation device. Int J Impot Res. 1996;8(4):221-225. [pmid: 8981171].
Clark C. Erectile dysfunction and other problems. Can Pharm J. 2004;272(7299):608-610.
Claro JA, Ximenes SF, Nardozza A, et al. Effect of sildenafil in cavernous arteries of patients with erectile dysfunction. International Braz J Urol. 2003;29(4):320-326. [pmid: 15745555].
Cohen JS. Comparison of FDA reports of patient deaths associated with sildenafil and with injectable alprostadil. Ann Pharmacother. 2001;35(3):285-288. [pmid: 11261524].
Conti CR, Pepine CJ, Sweeney M. Efficacy and safety of sildenafil citrate in the treatment of erectile dysfunction in patients with ischemic heart disease. Am J Cardiol. 1999;83(5A):29C-34C.
Cooper AJ. Evaluation of I-C papaverine in patients with psychogenic and organic impotence. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 1991;36(8):574-578. [pmid: 1742710].
Copel L, Katz R, Blachar A, et al. Clinical and duplex US assessment of effects of sildenafil on cavernosal arteries of the penis: Comparison with intracavernosal injection of vasoactive agents - Initial experience. Radiology. 2005;237(3):986-991. [pmid: 16237136].
Corona G, Mannucci E, Fisher AD, et al. Effect of hyperprolactinemia in male patients consulting for sexual dysfunction. Br J Sex Med. 2007;4(5):1485-1493.
Corona G, Mannucci E, Schulman C, et al. Psychobiologic correlates of the metabolic syndrome and associated sexual dysfunction. Eur Urol. 2006;50(3):595-604. [pmid: 16564129].
Costabile RA, Spevak M, Fishman IJ, et al. Efficacy and safety of transurethral alprostadil in patients with erectile dysfunction following radical prostatectomy. Br J Urol. 1998;160(4):1325-1328.
Crowe SM, Streetman DS. Vardenafil treatment for erectile dysfunction. [Review] [43 refs]. Ann Pharmacother. 2004;38(1):77-85. [pmid: 14742800].
Curran M, Keating G. Tadalafil.[erratum appears in Drugs. 2003;63(23):2703]. [Review] [31 refs]. Drugs. 2003;63(20):2203-2212. [pmid: 14498756].
Dachille G, Pagliarulo V, Ludovico GM, et al. Sexual dysfunction in patients under dialytic treatment. Minerva Urol Nefrol. 2006;58(2):195-200. [pmid: 16767073].
Davis BE, Weigel JW, Whitford CS. Treatment of male impotence: a new option. Kans Med. 1990;91(12):325-326. [pmid: 1705298].
De Rose AF, Giglio M, Traverso P, et al. Combined oral therapy with sildenafil and doxazosin for the treatment of non-organic erectile dysfunction refractory to sildenafil monotherapy. Int J Impot Res. 2002;14(1):50-53. [pmid: 11896478].
De Meyer JM, Thibo P, Hatzichriston DG. The effect of re-dosing of vasodilators on the intracavernosal pressure and on the penile rigidity. Eur Urol. 1998;33(3):293-297. [pmid: 9555555].
De Siati M, Saugo M, Franzolin N. The start of pharmacological activity after sublingual administration of sildenafil citrate in 30 patients affected by erectile dysfunction. Arch Ital Urol Androl. 2003;75(1):18-20. [pmid: 12741340].
Decter RM, Furness PD, Nguyen TA, et al. Reproductive understanding, sexual functioning and testosterone levels in men with spina bifida. Br J Urol. 1997;157(4):1466-1468.
Derby CA, Araujo AB, Johannes CB, et al. Measurement of erectile dysfunction in population-based studies: the use of a single question self-assessment in the Massachusetts Male Aging Study. Int J Impot Res. 2000;12(4):197-204. [pmid: 11079360].
Derry F, Hultling C, Seftel AD, et al. Efficacy and safety of sildenafil citrate (Viagra) in men with erectile dysfunction and spinal cord injury: a review. Urology. 2002;60(2 Suppl 2):49-57. [pmid: 12414333].
Dhabuwala CB, Kerkar P, Bhutwala A, et al. Intracavernous papaverine in the management of psychogenic impotence. Arch Androl. 1990;24(2):185-191. [pmid: 2327828].
Dinsmore WW. Medical treatment of impotence with papaverine and phentolamine intracavernosal injection. Ulster Med J. 1990;59(2):174-176. [pmid: 2278115].
Dinsmore WW, Alderdice DK. Vasoactive intestinal polypeptide and phentolamine mesylate administered by autoinjector in the treatment of patients with erectile dysfunction resistant to other intracavernosal agents. Br J Urol. 1998;81(3):437-440. [pmid: 9523666].
Dizon MN, Vesely DL. Gonadotropin-secreting pituitary tumor associated with hypersecretion of testosterone and hypogonadism after hypophysectomy. Endocr Pract. 2002;8(3):225-231. [pmid: 12113637].
Doggrell SA. Comparison of clinical trials with sildenafil, vardenafil and tadalafil in erectile dysfunction. Expert Opin Pharmacother. 2005;6(1):75-84. [pmid: 15709885].
Donatucci CF, Lue TF. Erectile dysfunction in men under 40: etiology and treatment choice. Int J Impot Res. 1993;5(2):97-103. [pmid: 8348217].
Donatucci C, Eardley I, Buvat J, et al. Vardenafil improves erectile function in men with erectile dysfunction irrespective of disease severity and disease classification. Br J Sex Med. 2004;1(3):301-309.
Dundar SO, Dayanir Y, Topalolu A, et al. Effect of sildenafil on ocular hemodynamics in 3 months regular use. Int J Impot Res. 2006;18(3):282-286. [pmid: 16292333].
Dundar SO, Topalolu A, Dundar M, et al. Effects of sildenafil on blue-on-yellow and white-on-white Humphrey perimetry in 3 months regular use. Arb Paul Ehrlich Inst Georg Speyer Haus Ferdinand Blum Inst Frankf A M. 2006;20(7):810-813.
Dunn A. Sildenafil: A new therapy for erectile dysfunction. Conn Med. 1998;62(7):413-416. [pmid: 9707795].
Dusing R. Effect of the angiotensin II antagonist valsartan on sexual function in hypertensive men. Blood Pressure Supplement. 2003;2:29-34. [pmid: 14761074].
Eardley I. New oral therapies for the treatment of erectile dysfunction. Br J Urol. 1998;81(1):122-127. [pmid: 9467488].
El Malik EMA. Erectile dysfunction: An update of diagnosis and management. Qatar Medical Journal. 2000;9(2):9-17.
El-Sakka AI. Efficacy of sildenafil citrate in treatment of erectile dysfunction: effect of type 2 diabetes. Eur Urol. 2004;46(4):503-509. [pmid: 15363568].
El-Sakka AI. Efficacy of sildenafil citrate in treatment of erectile dysfunction: impact of associated premature ejaculation and low desire. Urology. 2006;68(3):642-647. [pmid: 16979718].
El-Sakka AI, Hassoba HM, Elbakry AM, et al. Prostatic specific antigen in patients with hypogonadism: Effect of testosterone replacement. Br J Sex Med. 2005;2(2):235-240.
Elhanbly S, Schoor R, Elmogy M, et al. What nonresponse to intracavernous injection really indicates: a determination by quantitative analysis. Br J Urol. 2002;167(1):192-196.
Engel JD, McVary KT. Transurethral alprostadil as therapy for patients who withdrew from or failed prior intracavernous injection therapy. Urology. 1998;51(5):687-692. [pmid: 9610580].
Engelhardt PF, Daha LK, Zils T, et al. Acupuncture in the treatment of psychogenic erectile dysfunction: first results of a prospective randomized placebo-controlled study. Int J Impot Res. 2003;15(5):343-346. [pmid: 14562135].
Engelhardt PF, Plas E, Hubner WA, et al. Comparison of intraurethral liposomal and intracavernosal prostaglandin-E1 in the management of erectile dysfunction. Br J Urol. 1998;81(3):441-444. [pmid: 9523667].
Engl T, Beecken WD, Wolfram M, et al. Uropharmacology: Current and future strategies in the treatment of erectile dysfunction and benign prostate hyperplasia. International Journal of Clinical Pharmacology & Therapeutics. 2004;42(10):527-533. [pmid: 15516021].
English JC, King DHC, Foley JP. Penile shaft hypopigmentation: Lichen sclerosus occurring after the initiation of alprostadil intracavernous injections for erectile dysfunction. J Am Acad Dermatol. 1998;39(5 I):801-803. [pmid: 9810901].
Erbagci A, Yagci F, Sarica K, et al. Evaluation and therapeutic regulation of erectile dysfunction with visual stimulation test. An objective approach by using sildenafil citrate test. Urol Int. 2002;69(1):21-26. [pmid: 12119434].
Erdogru T, Usta MF, Ceken K, et al. Is sildenafil citrate an alternative agent in the evaluation of penile vascular system with color Doppler ultrasound?. Urol Int. 2002;68(4):255-260. [pmid: 12053028].
Ernst E, Pittler MH. Yohimbine for erectile dysfunction: a systematic review and meta-analysis of randomized clinical trials. J Urol. 1998;159(2):433-436. [pmid: 9649257].
Escobar-Jimenez F. [Efficacy and safety of sildenafil in men with type 2 diabetes mellitus and erectile dysfunction]. Med Clin (Barc). 2002;119(4):121-124. [pmid: 12106522].
Espinoza R, Melchor JL, Gracida C. Sildenafil (Viagra) in kidney transplant recipients with erectile dysfunction. Transplant Proc. 2002;34(1):408-409. [pmid: 11959347].
Fagelman E, Fagelman A, Shabsigh R. Efficacy, safety, and use of sildenafil in urologic practice. Urology. 2001;57(6):1141-1144. [pmid: 11377328].
Fava M, Rankin MA, Alpert JE, et al. An open trial of oral sildenafilin antidepressant-induced sexual dysfunction. Psychotherapy & Psychosomatics. 1998;67(6):328-331. [pmid: 9817955].
Fazeli-Matin S, Montague DK, Angermeier KW, et al. Penile fracture after intracavernous injection therapy. Br J Urol. 1998;159(6):2094.
Fedele D, Coscelli C, Cucinotta D, et al. Management of erectile dysfunction in diabetic subjects: results from a survey of 400 diabetes centres in Italy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14(5):277-282.
Fein RL. Classification of sexual dysfunction for management of intracavernous medication-induced erections.[see comment]. Br J Urol. 1990;143(2):298-301.
Feldman R, Meuleman EJ, Steers W. Sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction: analysis of two flexible dose-escalation studies. Sildenafil Study Group. Int J Clin Pract. 1999;102(Suppl Jun.):100-102.
Fink HA, Mac Donald R, Rutks IR, et al. Sildenafil for male erectile dysfunction: a systematic review and meta-analysis. Arch Intern Med. 2002;162(12):1349-1360. [pmid: 12076233].
Fink HA, MacDonald R, Rutks IR, et al. Trazodone for erectile dysfunction: a systematic review and meta-analysis. BJU Int. 2003;92(4):441-446. [pmid: 12930437].
Fishbain David A. Impact of sildenafil on male erectile disorder due to psychological factors. Can J Psychiatry. 2000;45(1):85-86. [pmid: 10696497].
Flack JM. The effect of doxazosin on sexual function in patients with benign prostatic hyperplasia, hypertension, or both.[see comment]. [Review] [47 refs]. Int J Clin Pract. 2002;56(7):527-530. [pmid: 12296615].
Fonseca V, Seftel A, Denne J, et al. Impact of diabetes mellitus on the severity of erectile dysfunction and response to treatment: analysis of data from tadalafil clinical trials. Diabetologia. 2004;47(11):1914-1923. [pmid: 15599697].
Foresta C, Caretta N, Lana A, et al. Relationship Between Vascular Damage Degrees and Endothelial Progenitor Cells in Patients with Erectile Dysfunction: Effect of Vardenafil Administration and PDE5 Expression in the Bone Marrow. Eur Urol. 2007;51(5):1411-1419. [pmid: 17034932].
Foresta C, Ferlin A, De Toni L, et al. Circulating endothelial progenitor cells and endothelial function after chronic Tadalafil treatment in subjects with erectile dysfunction. Int J Impot Res. 2006;18(5):484-488. [pmid: 16541115].
Foulks CJ, Cushner HM. Sexual dysfunction in the male dialysis patient: pathogenesis, evaluation, and therapy. [Review] [105 refs]. Am J Kidney Dis. 1986;8(4):211-222. [pmid: 3532769].
Fox KM, Thadani U, Ma PT, et al. Sildenafil citrate does not reduce exercise tolerance in men with erectile dysfunction and chronic stable angina. Eur Heart J. 2003;24(24):2206-2212. [pmid: 14659772].
Freitas D, Athanazio R, Almeida D, et al. Sildenafil improves quality of life in men with heart failure and erectile dysfunction. Int J Impot Res. 2006;18(2):210-212. [pmid: 16121207].
Fugl-Meyer AR, Lodnert G, Branholm IB, et al. On life satisfaction in male erectile dysfunction. Int J Impot Res. 1997;9(3):141-148. [pmid: 9315491].
Fugl-Meyer KS, Stothard D, Belger M, et al. The effect of tadalafil on psychosocial outcomes in Swedish men with erectile distress: a multicentre, non-randomised, open-label clinical study. Int J Clin Pract. 2006;60(11):1386-1393. [pmid: 17073836].
Fujisawa M, Sawada K. Clinical efficacy and safety of sildenafil in elderly patients with erectile dysfunction. Arch Androl. 2004;50(4):255-260. [pmid: 15277003].
Fulgham PF, Cochran JS, Denman JL, et al. Disappointing initial results with transurethral alprostadil for erectile dysfunction in a urology practice setting. Br J Urol. 1998;160(6 Pt 1):2041-2046.
Gana TE, Quizanos LF, Castell R, et al. A dose-response study of alprostadil in patients with erectile dysfunction. Curr Ther Res Clin Exp. 1996;57(9):700-710.
Garcia-Bravo AM, Suarez-Hernandez D, Ruiz-Fernandez MA, et al. Determination of changes in blood pressure during administration of sildenafil (Viagra) in patients with spinal cord injury and erectile dysfunction. Proc Annu Clin Spinal Cord Inj Conf. 2006;44(5):301-308.
Ghanem H, Sherif T, bdEl-Gawad T, et al. Short term use of intracavernous vasoactive drugs in the treatment of persistent psychogenic erectile dysfunction. Int J Impot Res. 1998;10(4):211-214. [pmid: 9884916].
Gheorghiu S, Godschalk M, Gentili A, et al. Quality of life in patients using self-administered intracavernous injections of prostaglandin E1 for erectile dysfunction. Br J Urol. 1996;156(1):80-81.
Giammusso B, Morgia G, Spampinato A, et al. Improved pallesthetic sensitivity of pudendal nerve in impotent diabetic patients treated with acetyl-L-carnitine. Acta Urologica Italica. 1996;10(3):185-187.
Gil A, Martinez E, Oyaguez I, et al. Erectile dysfunction in a primary care setting: results of an observational, no-control-group, prospective study with sildenafil under routine conditions of use. Int J Impot Res. 2001;13(6):338-347. [pmid: 11918250].
Gilbert HW, Gingell JC. The results of an intracorporeal papaverine clinic. Sex Marital Ther. 1991;6(1):49-56.
Gilbert HW, Gillatt DA, Desai KM, et al. Intracorporeal papaverine injection in androgen deprived men. J R Soc Med. 1990;83(3):161. [pmid: 2182861].
Gilbert R N, Graham C W, Regan J B. Double-blind- cross-over trial of testosterone enanthate in impotent men with low or low-normal serum testosterone levels. Br J Urol 1992;147264
Gillies HC, Roblin D, Jackson G. Coronary and systemic hemodynamic effects of sildenafil citrate: From basic science to clinical studies in patients with cardiovascular disease. Int J Cardiol. 2002;86(23):131-141. [pmid: 12419549].
Gingell C, Buvat J, Jardin A et al. Sildenafil citrate (VIAGRA(TM)), an oral treatment for erectile function: 1-year, open-label, extension studies. Int J Clin Pract 1999;(pp 30–31):-31.
Ginsberg DL. Vardenafil treatment of sertraline-induced sexual dysfunction. Primary Psychiatry. 2004;11(11):23-24.
Ginsberg David L. Sildenafil-dihydrocodeine interaction results in prolonged erections. [References]. Primary Psychiatry. 2003;10(2):23.
Ginzburg R, Wong Y, Fader JS. Effect of bupropion on sexual dysfunction. Ann Pharmacother. 2005;39(12):2096-2099. [pmid: 16288071].
Giuliano F, Donatucci C, Montorsi F, et al. Vardenafil is effective and well-tolerated for treating erectile dysfunction in a broad population of men, irrespective of age. BJU Int. 2005;95(1):110-116. [pmid: 15638906].
Giuliano F, Montorsi F, Mirone V, et al. Switching from intracavernous prostaglandin E1 injections to oral sildenafil citrate in patients with erectile dysfunction: results of a multicenter European study. The Sildenafil Multicenter Study Group. Br J Urol. 2000;164(3:Pt 1):t-11.
Giuliano F, Pena BM, Mishra A, et al. Efficacy results and quality-of-life measures in men receiving sildenafil citrate for the treatment of erectile dysfunction. Qual Life Res. 2001;10(4):359-369. [pmid: 11763248].
Giuliano F, Rubio-Aurioles E, Kennelly M, et al. Efficacy and safety of vardenafil in men with erectile dysfunction caused by spinal cord injury. Neurology. 2006;66(2):210-216. [pmid: 16434656].
Glenn DRJ, McClure N, Lewis SEM. The hidden impact of diabetes on male sexual dysfunction and fertility. Hum Fertil. 2003;6(4):174-179.
Glina S, Sotomayor M, Gatchalian E, et al. Timing of dose relative to sexual intercourse attempt in previous sildenafil citrate users treated with tadalafil. Br J Sex Med. 2006;3(2):309-319.
Godschalk MF, Chen J, Katz PG, et al. Prostaglandin E1 as treatment for erectile failure in elderly men. J Am Geriatr Soc. 1994;42(12):1263-1265. [pmid: 7983289].
Godschalk M, Gheorghiu D, Chen J, et al. Long-term efficacy of a new formulation of prostaglandin E1 as treatment for erectile failure. Br J Urol. 1996;155(3):915-917.
Gogtay NJ, Bichile SK, Pinto CJ, et al. Erectile dysfunction and sildenafil citrate.[comment]. J Assoc Physicians India. 2001;49:871-872. [pmid: 11837751].
Goldenberg MM. Safety and efficacy of sildenafil citrate in the treatment of male erectile dysfunction. Clin Ther. 1998;20(6):1033-1048. [pmid: 9916601].
Goldstein I. Oral phentolamine: an alpha-1, alpha-2 adrenergic antagonist for the treatment of erectile dysfunction. [Review][9 refs]. Int J Impot Res 2000;12Suppl-80.
Goldstein I. A 36-week, open label, non-comparative study to assess the long-term safety of sildenafil citrate (VIAGRA) in patients with erectile dysfunction. Int J Clin Pract 1999;Supplement.102–109.
Goldstein I, Auerbach S, Padma-Nathan H, et al. Axial penile rigidity as primary efficacy outcome during multi-institutional in-office dose titration clinical trials with alprostadil alfadex in patients with erectile dysfunction. Alprostadil Alfadex Study Group. Int J Impot Res. 2000;12(4):205-211. [pmid: 11079361].
Goldstein I, Kim E, Steers WD, et al. Efficacy and safety of tadalafil in men with erectile dysfunction with a high prevalence of comorbid conditions: results from MOMENTUS: multiple observations in men with erectile dysfunction in National Tadalafil Study in the US. Br J Sex Med. 2007;4(1):166-175.
Gomery P, Bullock A, McGettigan J, et al. Tadalafil is efficacious in Black American and Hispanic men with erectile dysfunction: results from multiple observations in men with erectile dysfunction in national tadalafil study in the US (MOMENTUS). Int J Impot Res. 2007;19(1):76-83. [pmid: 16728966].
Goonawardena SA, de Silva WA, Ketheeswaran T. Pharmacologically induced penile erections in the assessment and treatment of erectile impotence: a preliminary study of 100 patients. Ceylon Med J. 1997;42(2):72-74. [pmid: 9257465].
Gore JL, Swerdloff RS, Rajfer J. Androgen deficiency in the etiology and treatment of erectile dysfunction. Urol Clin North Am. 2005;32(4):457-468. [pmid: 16291037].
Govier FE, McClure RD, Weissman RM, et al. Experience with triple-drug therapy in a pharmacological erection program.[see comment]. Br J Urol. 1993;150(6):1822-1824.
Greco EA, Pili M, Bruzziches R, et al. Testosterone:estradiol ratio changes associated with long-term tadalafil administration: a pilot study. Br J Sex Med. 2006;3(4):716-722.
Greco E, Polonio-Balbi P. Penile rigidity in erectile dysfunction treated with alprostadil. Lancet. 1997;350(9092):1682. [pmid: 9400524].
Greco E, Balbi PP, Virag R. Self intra-cavernous injections as a successful treatment in pure neurogenic impotence. Riv Neurol. 1991;61(1):35-38. [pmid: 1857921].
Green BG, Martin S. Clinical assessment of sildenafil in the treatment of neurogenic male sexual dysfunction: After the hype. NeuroRehabilitation. 2000;15(2):101-105. [pmid: 11455087].
Greenstein A, Mabjeesh NJ, Sofer M, et al. Does sildenafil combined with testosterone gel improve erectile dysfunction in hypogonadal men in whom testosterone supplement therapy alone failed?[see comment]. Br J Urol. 2005;173(2):530-532.
Gresser U, Gleiter CH. Erectile dysfunction: comparison of efficacy and side effects of the PDE-5 inhibitors sildenafil, vardenafil and tadalafil—review of the literature. [Review] [92 refs]. Eur J Med Res. 2002;7(10):435-446. [pmid: 12435622].
Gross AJ, Sauerwein DH, Kutzenberger J, et al. Penile prostheses in paraplegic men. Br J Urol. 1996;78(2):262-264. [pmid: 8813925].
Grossman EB, Swan SK, Muirhead GJ, et al. The pharmacokinetics and hemodynamics of sildenafil citrate in male hemodialysis patients. Kidney Int. 2004;66(1):367-374. [pmid: 15200445].
Grover JK, Vats V, Ajeeta. Sildenafil (Viagra(TM)). Medico-Legal Update. 1998;3(12):67-78.
Guay AT, Perez JB, Jacobson J, et al. Efficacy and safety of sildenafil citrate for treatment of erectile dysfunction in a population with associated organic risk factors.[erratum appears in J Androl 2002 Jan-Feb;23(1):113]. J Androl. 2001;22(5):793-797. [pmid: 11545291].
Guay AT, Perez JB, Velasquez E, et al. Clinical experience with intraurethral alprostadil (MUSE) in the treatment of men with erectile dysfunction. A retrospective study. Medicated urethral system for erection. Eur Urol. 2000;38(6):671-676. [pmid: 11111182].
Guay AT, Spark RF, Jacobson J, et al. Yohimbine treatment of organic erectile dysfunction in a dose-escalation trial. Int J Impot Res. 2002;14(1):25-31. [pmid: 11896474].
Gupta N, Sawlani K K, Tripathi A K. Appropriate use of sildenafil citrate in male erectile dysfunction.[see comment]. [Review] [52 refs]. J Assoc Physicians India. 2001;49:889-896. [pmid: 11837756].
Gupta Sanjay, Masand Prakash, Ashton Adam K, et al. Phenelzine-induced sexual dysfunction treated with sildenafil. J Sex Marital Ther. 1999;25(2):131-135. [pmid: 10327382].
Gutierrez P, Hernandez P, Mas M. Combining programmed intracavernous PGE1 injections and sildenafil on demand to salvage sildenafil nonresponders. Int J Impot Res. 2005;17(4):354-358. [pmid: 15703770].
Hammadeh MY, Madaan S, Hines J, et al. 5-year outcome of a prospective randomized trial to compare transurethral electrovaporization of the prostate and standard transurethral resection. Urology. 2003;61(6):1166-1171. [pmid: 12809891].
Harding LM, Adeniyi A, Everson R, et al. Comparison of a needle-free high-pressure injection system with needle-tipped injection of intracavernosal alprostadil for erectile dysfunction. Int J Impot Res. 2002;14(6):498-501. [pmid: 12494285].
Harrold LR, Gurwitz JH, Field TS, et al. The diffusion of a novel therapy into clinical practice: the case of sildenafil.[see comment]. Arch Intern Med. 2000;160(22):3401-3405. [pmid: 11112232].
Harwood PJ, Grotz M, Eardley I, et al. Erectile dysfunction after fracture of the pelvis. Journal of Bone & Joint Surgery - British Volume. 2005;87(3):281-290.
Hatzichristou D G. Sildenafil citrate: lessons learned from 3 years of clinical experience. [Review][60 refs]. Int J Impot Res 2002;14Suppl-52.
Hatzichristou D G. Current treatment and future perspectives for erectile dysfunction. [Review][85 refs]. Int J Impot Res 1998;10Suppl-13.
Hatzichristou DG, Apostolidis A, Tzortzis V, et al. Sildenafil versus intracavernous injection therapy: efficacy and preference in patients on intracavernous injection for more than 1 year. Br J Urol. 2000;164(4):1197-1200.
Hatzichristou D, Vardi Y, Papp G, et al. Effect of tadalafil on sexual timing behavior patterns in men with erectile dysfunction: integrated analysis of randomized, placebo controlled trials. Br J Urol. 2005;174(4 Pt 1):1356-1359.
Hatzimouratidis K, Hatzichristou D. Phosphodiesterase Type 5 Inhibitors: The Day After. Eur Urol. 2007;51(1):75-89. [pmid: 16949200].
Hatzimouratidis K, Hatzichristou DG. A comparative review of the options for treatment of erectile dysfunction: Which treatment for which patient?. Drugs. 2005;65(12):1621-1650. [pmid: 16060698].
Hauck E W, Altinkilic B M, Schroeder-Printzen I et al. Prostaglandin E1 long-term self-injection programme for treatment of erectile dysfunction—a follow-up of at least 5 years. Andrologia 1999;31(Suppl):Suppl-103.
He XQ, Hong BF, Wang XX, et al. Evaluation of efficacy and safety of oral sildenafil citrate therapy for men with erectile dysfunction. Pharmaceutical Journal of Chinese Peoples Liberation Army. 2002;18(4):205-208.
Heaton JP. Key issues from the clinical trials of apomorphine SL. World J Urol. 2001;19(1):25-31. [pmid: 11289567].
Heaton JPW, Wagner Porst, Eid Wyllie. Apomorphine: An update of clinical trial results. Int J Impot Res. 2000;12(SUPPL. 4):S67-S73. [pmid: 11035390].
Heaton JP, Lording D, Liu SN, et al. Intracavernosal alprostadil is effective for the treatment of erectile dysfunction in diabetic men. Int J Impot Res. 2001;13(6):317-321. [pmid: 11918246].
Heaton JP, Morales A, Adams MA, et al. Recovery of erectile function by the oral administration of apomorphine. Urology. 1995;45(2):200-206. [pmid: 7855966].
Hellstrom WJ. Vardenafil: a new approach to the treatment of erectile dysfunction. [Review] [37 refs]. Curr Urol Rep. 2003;4(6):479-487. [pmid: 14622502].
Hirsch IH, Schanne FJ, Carsello J, et al. Sequential penile ultrasound monitoring of patients treated with chronic intracavernous prostaglandin E1. Urology. 1995;45(6):1037-1041. [pmid: 7771005].
Hirsch IH, Smith RL, Chancellor MB, et al. Use of intracavernous injection of prostaglandin E1 for neuropathic erectile dysfunction. Paraplegia. 1994;32(10):661-664. [pmid: 7831071].
Hollander JB, Gonzalez J, Norman T. Patient satisfaction with pharmacologic erection program. Urology. 1992;39(5):439-441. [pmid: 1580034].
Holmes S. Tadalafil: a new treatment for erectile dysfunction. BJU Int. 2003;91(6):466-468. [pmid: 12656894].
Hong EK, Lepor H, McCullough AR. Time dependent patient satisfaction with sildenafil for erectile dysfunction (ED) after nerve-sparing radical retropubic prostatectomy (RRP). Int J Impot Res. 1999;11(SUPPL. 1):S15-S22. [pmid: 10554925].
Hong JH, Ahn TY. Oral testosterone replacement in Korean patients with PADAM. Aging Male. 2002;5(1):52-56. [pmid: 12040976].
Hookes J. Asian Federation of Medicinal Chemistry (AFMC) - Fifth International Medicinal Chemistry Symposium: 14–17 October 2003, Kyoto, Japan. IDrugs. 2003;6(11):1013-1015. [pmid: 15270004].
Huang ST, Hsieh ML. Different hemodynamic responses by color Doppler ultrasonography studies between sildenafil non-responders and responders. Asian J Androl. 2007;9(1):129-133. [pmid: 17187164].
Hubler J, Szanto A, Konyves K. Methylene blue as a means of treatment for priapism caused by intracavernous injection to combat erectile dysfunction. International Urology & Nephrology. 2003;35(4):519-521. [pmid: 15198160].
Hwang TI, Chen HE, Tsai TF, et al. Combined use of androgen and sildenafil for hypogonadal patients unresponsive to sildenafil alone. Int J Impot Res. 2006;18(4):400-404. [pmid: 16395321].
Incrocci L, Hop WC, Slob AK. Visual erotic and vibrotactile stimulation and intracavernous injection in screening men with erectile dysfunction: a 3 year experience with 406 cases. Int J Impot Res. 1996;8(4):227-232. [pmid: 8981172].
Irwin MB, Kata EJ. High attrition rate with intracavernous injection of prostaglandin E1 for impotency. Urology. 1994;43(1):84-87. [pmid: 8284888].
Isidori AM, Giannetta E, Gianfrilli D, et al. Effects of testosterone on sexual function in men: results of a meta-analysis. Clin Endocrinol (Oxf). 2005;63(4):381-394. [pmid: 16181230].
Ismail M, Abbott L, Hirsch IH. Experience with intracavernous PGE-1 in the treatment of erectile dysfunction: dose considerations and efficacy. Int J Impot Res. 1997;9(1):39-42. [pmid: 9138057].
Israilov S, Niv E, Livne PM, et al. Intracavernous injections for erectile dysfunction in patients with cardiovascular diseases and failure or contraindications for sildenafil citrate. Int J Impot Res. 2002;14(1):38-43. [pmid: 11896476].
Israilov S, Shmuely J, Niv E, et al. Evaluation of a progressive treatment program for erectile dysfunction in patients with diabetes mellitus. Int J Impot Res. 2005;17(5):431-436. [pmid: 15889124].
Jackson G. Sildenafil (Viagra): New data, new confidence in treating erectile dysfunction in the cardiovascular patient. Int J Clin Pract. 2002;56(2):75. [pmid: 11926708].
Jackson G, Keltai M, Csanady M, et al. Hemodynamic effects of sildenafil citrate and isosorbide mononitrate in men with coronary artery disease and erectile dysfunction. Br J Sex Med. 2005;2(3):407-414.
Jackson G, Kloner RA, Costigan TM, et al. Update on clinical trials of tadalafil demonstrates no increased risk of cardiovascular adverse events. Br J Sex Med. 2004;1(2):161-167.
Jackson G, Montorsi P, Cheitlin MD. Cardiovascular safety of sildenafil citrate (Viagra): an updated perspective. [Review] [52 refs]. Urology. 2006;68(3 Suppl):47-60. [pmid: 17011375].
Jacobsen FM. Fluoxetine-induced sexual dysfunction and an open trial of yohimbine.[see comment]. Hillside J Clin Psychiatry. 1992;53(4):119-122.
Jain P, Rademaker AW, McVary KT. Testosterone supplementation for erectile dysfunction: results of a meta-analysis. Br J Urol. 2000;164(2):371-375.
Jarow JP, Burnett AL, Geringer AM. Clinical efficacy of sildenafil citrate based on etiology and response to prior treatment.[see comment]. Br J Urol. 1999;162(3:Pt 1):t-5.
Jiann BP, Yu CC, Su CC, et al. Rechallenge prior sildenafil nonresponders. Int J Impot Res. 2004;16(1):64-68. [pmid: 14963473].
Jiann BP, Yu CC, Tsai JY, et al. What to learn about sildenafil in the treatment of erectile dysfunction from 3-year clinical experience. Int J Impot Res. 2003;15(6):412-417. [pmid: 14671659].
Jiann BP, Yu CC, Su CC. Impact of introduction of sildenafil on other treatment modalities for erectile dysfunction: A study of nationwide and local hospital sales. Int J Impot Res. 2004;16(6):527-530. [pmid: 15229626].
John H, Lehmann K, Hauri D. Intraurethral prostaglandin improves quality of vacuum erection therapy. Eur Urol. 1996;29(2):224-226. [pmid: 8647152].
Juergense PH, Botev R, Wuerth D, et al. Erectile dysfunction in chronic peritoneal dialysis patients: incidence and treatment with sildenafil. Perit Dial Int. 2001;21(4):355-359. [pmid: 11587397].
Kadioglu A, Erdogru T, Tellaloglu S. Combined intracavernous injection of papaverine and stimulation (CIS) test. J Androl. 1994;15(Suppl):50S-53S. [pmid: 7721678].
Kaplan B, Ben-Rafael Z, Peled Y, et al. Oral sildenafil may reverse secondary ejaculatory dysfunction during infertility treatment. Fertility & Sterility. 1999;72(6):1144-1145. [pmid: 10593398].
Kaplan Helen S. The combined use of sex therapy and intrapenile injections in the treatment of impotence. J Sex Marital Ther. 1990;16(4):195-207. [pmid: 2079703].
Kaplan SA, Reis RB, Kohn IJ, et al. Combination therapy using oral alpha-blockers and intracavernosal injection in men with erectile dysfunction. Urology. 1998;52(5):739-743. [pmid: 9801091].
Karabulut A, Peskircioglu L, Ozkardes H, et al. Objective penile vascular response to intraurethral prostaglandin E2 (dinoprostone). Urol Int. 2001;67(2):160-162. [pmid: 11490212].
Kassouf W, Carrier S. A comparison of the International Index of Erectile Function and erectile dysfunction studies. BJU Int. 2003;91(7):667-669. [pmid: 12699481].
Katlowitz NM, Albano GJ, Morales P, et al. Potentiation of drug-induced erection with audiovisual sexual stimulation. Urology. 1993;41(5):431-434. [pmid: 8488610].
Katlowitz N, Albano GJ, Patsias G, et al. Effect of multidose intracorporeal injection and audiovisual sexual stimulation in vasculogenic impotence. Urology. 1993;42(6):695-697. [pmid: 8256402].
Kattan SA. The acceptance of satisfaction of Saudi males to vasoactive autoinjection intracavernous therapy, external negative pressure device and penile prosthesis in the treatment of erectile dysfunction. Ann Saudi Med. 2002;22(34):149-152. [pmid: 17159384].
Kaufman JM, Hatzichristou DG, Mulhall JP, et al. Impotence and chronic renal failure: a study of the hemodynamic pathophysiology. Br J Urol. 1994;151(3):612-618.
Keating GM, Scott LJ. Vardenafil: a review of its use in erectile dysfunction. Drugs. 2003;63(23):2673-2703. [pmid: 14636086].
Keating GM, Scott LJ. Spotlight on vardenafil in erectile dysfunction. Drugs Aging. 2004;21(2):135-140. [pmid: 14960129].
Kedia S, Zippe CD, Agarwal A, et al. Treatment of erectile dysfunction with sildenafil citrate (Viagra) after radiation therapy for prostate cancer. Urology. 1999;54(2):308-312. [pmid: 10443730].
Kendirci M, Bivalacqua TJ, Hellstrom WJ. Vardenafil: a novel type 5 phosphodiesterase inhibitor for the treatment of erectile dysfunction. Expert Opin Pharmacother. 2004;5(4):923-932. [pmid: 15102574].
Khan MA, Raistrick M, Mikhailidis DP, et al. MUSE: clinical experience. Current Medical Research & Opinion. 2002;18(2):64-67. [pmid: 12017211].
Khan MM, Khwaja M. Open label study of intracavernous injection of alpostadil alphadex in the treatment of erectile dysfunction. J Postgrad Med Inst. 2005;19(1):52-57.
Kim ED, McVary KT. Topical prostaglandin-E1 for the treatment of erectile dysfunction. Br J Urol. 1995;153(6):1828-1830.
Kim ED, el-Rashidy R, McVary KT. Papaverine topical gel for treatment of erectile dysfunction. Br J Urol. 1995;153(2):361-365.
Kim JM, Joh YD, Huh JD, et al. Doppler sonography of the penile cavernosal artery: comparison of intraurethral instillation and intracorporeal injection of prostaglandin E1. J Clin Ultrasound. 2001;29(5):273-278. [pmid: 11486321].
Kim NN, Christianson DW, Traish AM. Role of arginase in the male and female sexual arousal response. Br J Nutr. 2004;134(10 SUPPL.):2873S-2879S.
Kim SC, Ahn TY, Choi HK, et al. Multicenter study of the treatment of erectile dysfunction with transurethral alprostadil (MUSE) in Korea. Int J Impot Res. 2000;12(2):97-101. [pmid: 11052635].
Kim SC, Chang IH, Jeon HJ. Preference for oral sildenafil or intracavernosal injection in patients with erectile dysfunction already using intracavernosal injection for > 1 year. BJU Int. 2003;92(3):277-280. [pmid: 12887483].
Kim SC, Lee SW, Seo KK. Characteristics of pain following intracavernous injection of prostaglandin E1. J Korean Med Sci. 1997;12(4):327-331. [pmid: 9288633].
Kloner RA. Cardiovascular risk and sildenafil. [Review] [27 refs]. Am J Cardiol. 2000;86(2A):57F-61F.
Kloner RA, Zusman RM. Cardiovascular effects of sildenafil citrate and recommendations for its use. [Review] [21 refs]. Am J Cardiol. 1999;84(5B):11N-17N.
Kloner RA, Brown M, Prisant LM, et al. Effect of sildenafil in patients with erectile dysfunction taking antihypertensive therapy. Sildenafil Study Group. Am J Hypertens. 2001;14(1):70-73. [pmid: 11206684].
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil in patients on common antihypertensive therapies. [Review] [5 refs]. Am J Cardiol. 2003;92(9A):47M-57M. [pmid: 12842244].
Kloner RA, Mitchell M, Emmick JT. Cardiovascular effects of tadalafil. [Review] [12 refs]. Am J Cardiol. 2003;92(9A):37M-46M.
Kloner RA, Sadovsky R, Johnson EG, et al. Efficacy of tadalafil in the treatment of erectile dysfunction in hypertensive men on concomitant thiazide diuretic therapy. Int J Impot Res. 2005;17(5):450-454. [pmid: 16015377].
Kloner RA, Sadovsky R, Johnson EG, et al. Efficacy of tadalafil in the treatment of erectile dysfunction in hypertensive men on concomitant thiazide diuretic therapy. Br J Urol. 2006;175(4):1450.
Knispel HH. Penile venous surgery in impotence: results in highly selected cases. Urol Int. 1991;47(3):144-148. [pmid: 1771702].
Knispel HH, Huland H. Influence of cause on choice of therapy in 174 patients with erectile dysfunction. Br J Urol. 1992;147(5):1274-1276.
Koksal M, Ozdemir H, Kargi S, et al. The effects of sildenafil on ocular blood flow. Acta Ophthalmol Scand. 2005;83(3):355-359. [pmid: 15948790].
Kongkanand A, Opanuraks J, Tantiwongse K, et al. Evaluating dose regimens of apomorphine, an open-label study. Int J Impot Res. 2003;15(Suppl 2):10-12. [pmid: 12605235].
Kongkanand A, Ratana-Olarn K, Wuddhikarn S, et al. Evaluation of transurethal alprostadil for safety and efficacy in men with erectile dysfunction. J Med Assoc Thai. 2002;85(2):223-228. [pmid: 12081123].
Kramer-Levien D J. Papaverine—the medical implant. AUAA J 1987;7(4):13-Jun.
Kriston L, Harms A, Berner MM. A meta-regression analysis of treatment effect modifiers in trials with flexible-dose oral sildenafil for erectile dysfunction in broad-spectrum populations. Int J Impot Res. 2006;18(6):559-565. [pmid: 16688210].
Kromann-Andersen B. Intracavernosal pharmacotherapy with injection pen. Lancet. 1988;1(85756):54-59. [pmid: 2891913].
Kuba R, Pohanka M, Zakopcan J, et al. Sexual dysfunctions and blood hormonal profile in men with focal epilepsy. Epilepsia. 2006;47(12):2135-2140. [pmid: 17201714].
Kunelius P, Lukkarinenl O. Intracavernous self-injection of prostaglandin E1 in the treatment of erectile dysfunction. Int J Impot Res. 1999;11(1):21-24. [pmid: 10098949].
Kuzmarov IW, Ross D, Skamene A, et al. A sexual tune-up program as an adjunct to intracavernous pharmacotherapy. Can J Hum Sex. 1993;2(4):239-241.
Labbate Lawrence A, Grimes Jamie B, Hines Alan, et al. Bupropion treatment of serotonin reuptake antidepressant-associated sexual dysfunction. Ann Clin Psychiatry. 1997;9(4):241-245. [pmid: 9511948].
Lakin MM, Montague DK, VanderBrug Medendorp S, et al. Intracavernous injection therapy: Analysis of results and complications. Br J Urol. 1990;143(6):1138-1141.
Lal S, Kiely ME, Thavundayil JX, et al. Effect of bromocriptine in patients with apomorphine-responsive erectile impotence: an open study. J Psychiatry Neurosci. 1991;16(5):262-266. [pmid: 1797100].
Lance R, Albo M, Costabile RA, et al. Oral trazodone as empirical therapy for erectile dysfunction: a retrospective review. Urology. 1995;46(1):117-120. [pmid: 7604472].
Lane BZ, Ausmundson SJ, Butler RS, et al. Use of a visual analog scale to assess pain of injection with intracavernous injection therapy. Br J Sex Med. 2005;2(3):428-431.
Laties A, Sharlip I. Ocular safety in patients using sildenafil citrate therapy for erectile dysfunction. [Review] [81 refs]. Br J Sex Med. 2006;3(1):12-27.
Laties AM, Zrenner E. Viagra (sildenafil citrate) and ophthalmology. Progress in Retinal & Eye Research. 2002;21(5):485-506. [pmid: 12207947].
Laties A M, Fraunfelder F T, Flach A J et al. Ocular safety of Viagra, (sildenafil citrate). Trans Am Ophthalmol Soc 1999;97(pp 115–128):-128.
Lawless C, Cree J. Oral medications in the management of erectile dysfunction. [Review] [15 refs]. J Am Board Fam Pract. 1998;11(4):307-314. [pmid: 9719353].
Lawless C, Force RW. Sildenafil for erectile dysfunction. J Fam Pract. 1998;47(2):97-98. [pmid: 9722794].
Lawrence IG, Price DE, Howlett TA, et al. Correcting impotence in the male dialysis patient: experience with testosterone replacement and vacuum tumescence therapy. Am J Kidney Dis. 1998;31(2):313-319. [pmid: 9469503].
Le Bon O, Lion K, Verbanck P, et al. Fluparoxan in male erectile disorder: A case report. Yakubutsu Seishin Kodo. 1995;9(1):67-68.
Lea AP, Bryson HM, Balfour JA. Intracavernous alprostadil. A review of its pharmacodynamic and pharmacokinetic properties and therapeutic potential in erectile dysfunction. [Review] [123 refs]. Drugs Aging. 1996;8(1):56-74. [pmid: 8785470].
Lee J, Pommerville P, Brock G, et al. Physician-rated patient preference and patient- and partner-rated preference for tadalafil or sildenafil citrate: results from the Canadian ‘Treatment of Erectile Dysfunction’ observational study. BJU Int. 2006;98(3):623-629. [pmid: 16925764].
Lee W R. The role of androgen deprivation therapy combined with prostate brachytherapy. [Review][31 refs]. Urology 2002;60(3:Suppl 1):Suppl-44.
Levine LA, Latchamsetty KC. Treatment of erectile dysfunction in patients with Peyronie's disease using sildenafil citrate. Int J Impot Res. 2002;14(6):478-482. [pmid: 12494281].
Levitt EE, Mulcahy JJ. The effect of intracavernosal injection of papaverine hydrochloride on orgasm latency. Br J Sex Med. 1995;21(1):39-42.
Lewis RL, Sadovsky R, Eardley I, et al. The efficacy of tadalafil in clinical populations. Br J Sex Med. 2005;2(4):517-531.
Lewis RW. Intraurethral and topical agents. Med Actual. 2000;36(23):113-119.
Li MK, Lim PH, Wong MY, et al. Transurethral alprostadil for the treatment of erectile dysfunction: results of a multicentre trial. Ann Acad Med Singapore. 2000;29(6):727-731. [pmid: 11269978].
Lim PH, Ng FC. Erectile dysfunction in Singapore men: presentation, diagnosis, treatment and results. Ann Acad Med Singapore. 1992;21(2):248-253. [pmid: 1519896].
Lim PHC, Man KL, Foo CN, et al. Clinical efficacy and safety of sildenafil citrate (Viagra) in a multi-racial population in Singapore: A retrospective study of 1520 patients. Int J Urol. 2002;9(6):308-315. [pmid: 12110094].
Liu LC, Wu CC, Liu LH, et al. Comparison of the effects of papaverine versus prostaglandin E1 on penile blood flow by color duplex sonography. Eur Urol. 1991;19(1):49-53. [pmid: 2007418].
Livi U, Faggian G, Sorbara C, et al. Use of prostaglandin E1 in the treatment of sexual impotence after heart transplantation: initial clinical experience. Journal of Heart & Lung Transplantation. 1993;12(3):484-486. [pmid: 8329422].
Lombardo T, Giammusso B, Frontini V, et al. Thalassaemic men affected by erectile dysfunction treated with transurethral alprostadil: case report. Hum Reprod. 2000;15(11):2375-2378. [pmid: 11056136].
Long RL, Sherman LS, Lombardi TJ. A goal-oriented, cost-effective approach to the diagnosis and treatment of 24 male erectile dysfunction. [Review] [24 refs]. J Ky Med Assoc. 1995;93(11):500-508. [pmid: 8778212].
Lottman PE, Hendriks JC, Vruggink PA, et al. The impact of marital satisfaction and psychological counselling on the outcome of ICI-treatment in men with ED. Int J Impot Res. 1998;10(2):83-87. [pmid: 9647943].
Lowentritt BH, Scardino PT, Miles BJ, et al. Sildenafil citrate after radical retropubic prostatectomy. Br J Urol. 1999;162(5):1614-1617.
Lowy M, Collins S, Bloch M, et al. Quality of erection questionnaire correlates: change in erection quality with erectile function, hardness, and psychosocial measures in men treated with sildenafil for erectile dysfunction. Br J Sex Med. 2007;4(1):83-92.
Lue TF. Impotence after radical pelvic surgery: physiology and management. [Review] [56 refs]. Urol Int. 1991;46(3):259-265. [pmid: 1926639].
Lukkarinen O, Tonttila P, Hellstrom P, et al. Non-prosthetic surgery in the treatment of erectile dysfunction. A retrospective study of 45 impotent patients in the University of Oulu. Scandinavian Journal of Urology & Nephrology. 1998;32(1):42-46. [pmid: 9561573].
Lundberg L, Olsson JO, Kihl B. Long-term experience of self-injection therapy with prostaglandin E1 for erectile dysfunction. Scand J Urol Nephrol. 1996;30(5):395-397. [pmid: 8936629].
Lunenfeld B. Androgen therapy in the aging male. [Review] [110 refs]. World J Urol. 2003;21(5):292-305. [pmid: 14576959].
Magoha GA. Sildenafil (Viagra) in the treatment of male erectile dysfunction in Nairobi. East Afr Med J. 2000;77(2):76-79. [pmid: 10774079].
Manecke RG, Mulhall JP. Medical treatment of erectile dysfunction. [Review] [69 refs]. Ann Med. 1999;31(6):388-398. [pmid: 10680853].
Maniam P, Seftel AD, Corty EW, et al. Nocturnal penile tumescence activity unchanged after long-term intracavernous injection therapy. Br J Urol. 2001;165(3):830-832.
Mansi MK, Alkhudair WK, Huraib S. Treatment of erectile dysfunction after kidney transplantation with intracavernosal self-injection of prostaglandin E1. Br J Urol. 1998;159(6):1927-1930.
Marberger M, Roehrborn CG, Marks LS, et al. Relationship among serum testosterone, sexual function, and response to treatment in men receiving dutasteride for benign prostatic hyperplasia. Journal of Clinical Endocrinology & Metabolism. 2006;91(4):1323-1328. [pmid: 16434455].
Mark SD, Keane TE, Vandemark RM, et al. Impotence following pelvic fracture urethral injury: incidence, aetiology and management. Br J Urol. 1995;75(1):62-64. [pmid: 7850299].
Markou S, Perimenis P, Gyftopoulos K, et al. Vardenafil (Levitra) for erectile dysfunction: a systematic review and meta-analysis of clinical trial reports. Int J Impot Res. 2004;16(6):470-478. [pmid: 15229625].
Marks LS, Duda C, Dorey FJ, et al. Treatment of erectile dysfunction with sildenafil.[see comment]. Urology. 1999;53(1):19-24. [pmid: 9886582].
Marshall GA, Breza J, Lue TF. Improved hemodynamic response after long-term intracavernous injection for impotence. Urology. 1994;43(6):844-848. [pmid: 8197648].
Martin-Morales A, Haro JM, Beardsworth A, et al. Therapeutic effectiveness and patient satisfaction after 6 months of treatment with tadalafil, sildenafil, and vardenafil: results from the erectile dysfunction observational study (EDOS). Eur Urol. 2007;51(2):541-550. [pmid: 17084518].
Martin-Morales A, Moncada Iribarren I, Cruz Navarro N, et al. [Efficacy and safety of two dosing regimens with Tadalafil in Spanish men with erectile dysfunction: results from the SURE study in 14 European countries]. Actas Urol Esp. 2006;30(8):791-800. [pmid: 17078576].
Martinez R, Puigvert A, Pomerol JM, et al. Clinical experience with apomorphine hydrochloride: the first 107 patients. Br J Urol. 2003;170(6:Pt 1):t-5.
Martinez-Jabaloyas JM, Gil-Salom M, Villamon-Fort R, et al. Prognostic factors for response to sildenafil in patients with erectile dysfunction. Eur Urol. 2001;40(6):641-647. [pmid: 11805410].
Martinez-Pineiro L, Cortes R, Cuervo E, et al. Prospective comparative study with intracavernous sodium nitroprusside and prostaglandin E1 in patients with erectile dysfunction. Eur Urol. 1998;34(4):350-354. [pmid: 9748684].
Matthew AG, Goldman A, Trachtenberg J, et al. Sexual dysfunction after radical prostatectomy: Prevalence, treatments, restricted use of treatments and distress. Br J Urol. 2005;174(6):2105-2110.
Maytom MC, Derry FA, Dinsmore WW, et al. A two-part pilot study of sildenafil (VIAGRA) in men with erectile dysfunction caused by spinal cord injury. Spinal Cord. 1999;37(2):110-116. [pmid: 10065749].
McClure RD. Endocrine evaluation and therapy of erectile dysfunction. [Review] [77 refs]. Urol Clin North Am. 1988;15(1):53-64. [pmid: 3278476].
McClure RD, Oses R, Ernest ML. Hypogonadal impotence treated by transdermal testosterone. Urology. 1991;37(3):224-228. [pmid: 2000678].
McConnell JD, Roehrborn CG, Bautista OM, et al. The Long-Term Effect of Doxazosin, Finasteride, and Combination Therapy on the Clinical Progression of Benign Prostatic Hyperplasia. N Engl J Med. 2003;349(25):2387-2398. [pmid: 14681504].
McCullough AR, Barada JH, Fawzy A, et al. Achieving treatment optimization with sildenafil citrate (Viagra) in patients with erectile dysfunction. Urology. 2002;60(2 Suppl 2):28-38. [pmid: 12414331].
McCullough AR, Carson CC, Hatzichristou D. A prospective study of the beneficial effects of dose optimization and customized instructions on patient satisfaction with sildenafil citrate (Viagra) for erectile dysfunction. Urology. 2006;68(3 Suppl):38-46. [pmid: 17011374].
McMahon C. Comparison of erectile responses to differing doses of prostaglandin PGE1 in an attempt to standardise pharmacological diagnosis of impotence. Journal of Assisted Reproduction & Genetics 1992;9265A
McMahon C. Efficacy and safety of daily tadalafil in men with erectile dysfunction previously unresponsive to on-demand tadalafil. Br J Sex Med. 2004;1(3):292-300.
McMahon CG. High dose sildenafil citrate as a salvage therapy for severe erectile dysfunction. Int J Impot Res. 2002;14(6):533-538. [pmid: 12494291].
McMahon CG. An attempt to standardize the pharmacological diagnostic screening of vasculogenic impotence with prostaglandin E1. Int J Impot Res. 1995;7(2):83-90. [pmid: 7496445].
McMahon CG. Topiglan: MacroChem. Curr Opin Investig Drugs. 2002;3(4):602-606.
McMahon CG. A pilot study of the role of intracavernous injection of vasoactive intestinal peptide (VIP) and phentolamine mesylate in the treatment of erectile dysfunction. Int J Impot Res. 1996;8(4):233-236. [pmid: 8981173].
McMahon CG. Priapism associated with concurrent use of phosphodiesterase inhibitor drugs and intracavernous injection therapy. Int J Impot Res. 2003;15(5):383-384. [pmid: 14562142].
McMahon CG, Samali R, Johnson H. Efficacy, safety and patient acceptance of sildenafil citrate as treatment for erectile dysfunction. Br J Urol. 2000;164(4):1192-1196.
McMahon CG, Samali R, Johnson H. Treatment of intracorporeal injection nonresponse with sildenafil alone or in combination with triple agent intracorporeal injection therapy. Br J Urol. 1997;162(6):1992-1997.
McMahon C, Lording D, Stuckey B, et al. Vardenafil improved erectile function in a "real-life" broad population study of men with moderate to severe erectile dysfunction in Australia and New Zealand. Br J Sex Med. 2006;3(5):892-900.
McVary KT, Polepalle S, Riggi S, et al. Topical prostaglandin E1 SEPA gel for the treatment of erectile dysfunction. Br J Urol. 1999;162(3 Pt 1):732.
Mealy NE. Alprostadil cream. Drugs of the Future. 2004;29(6):626-627.
Mealy NE, Bayes M. PT-141. Drugs of the Future. 2004;29(11):1177.
Mehdiyev T V. Intracavernous injection probe of vasoactive preparations in the diagnosis of erectile dysfunctions in patients with diabetes mellitus. Azerbaidzhanskii Meditsinskii Zhurnal 2002;(pp 17–19):-19.
Meinhardt W, de la, Fuente RB, et al. Prostaglandin E1 with phentolamine for the treatment of erectile dysfunction. Int J Impot Res. 1996;8(1):5-7. [pmid: 8735187].
Meinhardt W, Nijeholt AA, Kropman RF, et al. Comparison of a mixture of papaverine, phentolamine and prostaglandin E1 with other intracavernous injections. Eur Urol. 1994;26(4):319-321. [pmid: 7713130].
Mellinger BC, Fried JJ, Darracott Vaughan. Papaverine-induced penile blood flow acceleration in impotent men measured by duplex scanning. Br J Urol. 1990;144(4):897-899.
Merrick GS, Butler WM, Lief JH, et al. Efficacy of sildenafil citrate in prostate brachytherapy patients with erectile dysfunction. Urology. 1999;53(6):1112-1116. [pmid: 10367837].
Metawea B, El-Nashar AR, Gad-Allah A, et al. Intracavernous papaverine/phentolamine-induced priapism can be accurately predicted with color Doppler ultrasonography. Urology. 2005;66(4):858-860. [pmid: 16230153].
Meyhoff HH, Rosenkilde P, Bodker A. Non-invasive management of impotence with transcutaneous nitroglycerin. Br J Urol. 1992;69(1):88-90. [pmid: 1737261].
Mikhail N. Does Testosterone Have a Role in Erectile Function?. Am J Med. 2006;119:373-382. [pmid: 16651047].
Millard RJ, Stricker PD, Lynch WJ, et al. Risks of self-injection therapy for impotence. Med J Aust. 1996;165(2):117-118. [pmid: 8692055].
Miller N, Smolkin ME, Bissonette E, et al. Undetectable prostate specific antigen at 6–12 months: a new marker for early success in hormonally treated patients after prostate brachytherapy. Cancer. 2005;103(12):2499-2506. [pmid: 15852361].
Mills TM, Lewis RW. The role of androgens in the erectile response: A 1999 perspective. Mol Urol. 1999;3(2):75-80. [pmid: 10851308].
Mirone VG, Stief CG. Efficacy of apomorphine SL in erectile dysfunction.[erratum appears in BJU Int 2002 Jan;89(1):140]. [Review] [11 refs]. BJU Int. 2001;88(Suppl 3):25-29. [pmid: 11578276].
Mirone V, Imbimbo C, Fabrizio F, et al. Ketanserin plus prostaglandin E1 (PGE-1) as intracavernosal therapy for patients with erectile dysfunction unresponsive to PGE-1 alone. Br J Urol. 1996;77(5):736-739. [pmid: 8689122].
Mirone V, Palmieri A, Cucinotta D, et al. Flexible-dose vardenafil in a community-based population of men affected by erectile dysfunction: a 12-week open-label, multicenter trial. Br J Sex Med. 2005;2(6):842-847.
Mittleman MA, Glasser DB, Orazem J. Clinical trials of sildenafil citrate (Viagra) demonstrate no increase in risk of myocardial infarction and cardiovascular death compared with placebo. Int J Clin Pract. 2003;57(7):597-600. [pmid: 14529061].
Mittleman MA, Maclure M, Glasser DB. Evaluation of acute risk for myocardial infarction in men treated with sildenafil citrate. Am J Cardiol. 2005;96(3):443-446. [pmid: 16054479].
Moemen MN, Hamed HA, Kamel II, et al. Clinical and sonographic assessment of the side effects of intracavernous injection of vasoactive substances. Int J Impot Res. 2004;16(2):143-145. [pmid: 15014552].
Moncada I, Jara J, Subira D, et al. Efficacy of sildenafil citrate at 12 hours after dosing: re-exploring the therapeutic window. Eur Urol. 2004;46(3):357-360. [pmid: 15306108].
Montorsi F, Althof SE. Partner responses to sildenafil citrate (Viagra) treatment of erectile dysfunction. Urology. 2004;63(4):762-767. [pmid: 15072897].
Montorsi F, McCullough A. Efficacy of sildenafil citrate in men with erectile dysfunction following radical prostatectomy: A systematic review of clinical data. Br J Sex Med. 2005;2(5):658-667.
Montorsi F, Althof SE, Sweeney M, et al. Treatment satisfaction in patients with erectile dysfunction switching from prostaglandin E(1) intracavernosal injection therapy to oral sildenafil citrate. Int J Impot Res. 2003;15(6):444-449. [pmid: 14671665].
Montorsi F, Briganti A, Salonia A, et al. Can Phosphodiesterase Type 5 Inhibitors Cure Erectile Dysfunction?. Eur Urol. 2006;49(6):979-986. [pmid: 16431013].
Montorsi F, Guazzoni G, Barbieri L, et al. The effect of intracorporeal injection plus genital and audiovisual sexual stimulation versus second injection on penile color Doppler sonography parameters. Br J Urol. 1996;155(2):536-540.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Effectiveness and safety of multidrug intracavernous therapy for vasculogenic impotence. Urology. 1993;42(5):554-558. [pmid: 7694416].
Montorsi F, Guazzoni G, Bergamaschi F, et al. Four-drug intracavernous therapy for impotence due to corporeal veno-occlusive dysfunction. Br J Urol. 1993;149(5 Pt 2):1291-1295.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Intracavernous vasoactive pharmacotherapy: the impact of a new self-injection device.[see comment]. Br J Urol. 1993;150(6):1829-1832.
Montorsi F, Guazzoni G, Bergamaschi F, et al. Clinical reliability of multi-drug intracavernous vasoactive pharmacotherapy for diabetic impotence. Acta Diabetol Lat. 1994;31(1):1-5.
Montorsi F, Hellstrom WJ, Valiquette L, et al. Vardenafil provides reliable efficacy over time in men with erectile dysfunction. Urology. 2004;64(6):1187-1195. [pmid: 15596195].
Montorsi F, Perani D, Anchisi D, et al. Apomorphine-induced brain modulation during sexual stimulation: a new look at central phenomena related to erectile dysfunction. Int J Impot Res. 2003;15(3):203-209. [pmid: 12904807].
Montorsi F, Salonia A, Briganti A, et al. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol. 2005;47(5):612-621. [pmid: 15826752].
Montorsi F, Verheyden B, Meuleman E, et al. Long-term safety and tolerability of tadalafil in the treatment of erectile dysfunction. Eur Urol. 2004;45(3):339-344. [pmid: 15036680].
Moore R A, Derry S, McQuay H J. Indirect comparison of interventions using published randomised trials: systematic review of PDE-5 inhibitors for erectile dysfunction. [Review][77 refs]. BMC Urol 2005;518
Moore R A, Edwards J E, McQuay H J. Sildenafil (Viagra) for male erectile dysfunction: a meta-analysis of clinical trial reports. BMC Urol. 2002;26
Morales A, Gingell C, Collins M, et al. Clinical safety of oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):69-73. [pmid: 9647940].
Morales A, Johnston B, Heaton JP, et al. Testosterone supplementation for hypogonadal impotence: assessment of biochemical measures and therapeutic outcomes. Br J Urol. 1997;157(3):849-854.
Morales A, Johnston B, Heaton JW, et al. Oral androgens in the treatment of hypogonadal impotent men.[see comment]. Br J Urol. 1994;152(4):1115-1118.
Morgentaler A, Barada J, Niederberger C, et al. Efficacy and safety of tadalafil across ethnic groups and various risk factors in men with erectile dysfunction: Use of a novel noninferiority study design. Br J Sex Med. 2006;3(3):492-503.
Mulhall JP. Deciphering erectile dysfunction drug trials. [Review] [35 refs]. Br J Urol. 2003;170(2 Pt 1):353-358.
Mulhall JP. Sublingual apomorphine for the treatment of erectile dysfunction. [Review] [22 refs]. Expert Opin Investig Drugs. 2002;11(2):295-302.
Mulhall JP, Bukofzer S, Edmonds AL, et al. An open-label, uncontrolled dose-optimization study of sublingual apomorphine in erectile dysfunction. Clin Ther. 2001;23(8):1260-1271. [pmid: 11558862].
Mulhall JP, Guhring P, Parker M, et al. Assessment of the impact of sildenafil citrate on lower urinary tract symptoms in men with erectile dysfunction. Br J Sex Med. 2006;3(4):662-667.
Mulhall JP, Jahoda AE, Ahmed A, et al. Analysis of the consistency of intraurethral prostaglandin E(1) (MUSE) during at-home use. Urology. 2001;58(2):262-266. [pmid: 11489714].
Mulhall JP, Jahoda AE, Cairney M, et al. The causes of patient dropout from penile self-injection therapy for impotence. Br J Urol. 1999;162(4):1291-1294.
Mulhall JP, Jahoda A, Aviv N, et al. The impact of sildenafil citrate on sexual satisfaction profiles in men with a penile prosthesis in situ. BJU Int. 2004;93(1):97-99. [pmid: 14678377].
Mulhall JP, Land S, Parker M, et al. The use of an erectogenic pharmacotheraphy regimen following radical prostatectomy improves recovery of spontaneous erectile function. Br J Sex Med. 2005;2(4):532-542.
Mulhall JP, Levine LA, Junemann KP. Erection hardness: a unifying factor for defining response in the treatment of erectile dysfunction. [Review] [37 refs]. Urology. 2006;68(3 Suppl):17-25. [pmid: 17011372].
Mulhall J, Barnas J, Aviv N, et al. Sildenafil citrate response correlates with the nature and the severity of penile vascular insufficiency. Br J Sex Med. 2005;2(1):104-108.
Muller MJ, Benkert O. Lower self-reported depression in patients with erectile dysfunction after treatment with sildenafil. J Affect Disord. 2001;66(23):255-261. [pmid: 11578679].
Muller MJ, Ruof J, Graf-Morgenstern M, et al. Quality of partnership in patients with erectile dysfunction after sildenafil treatment. Pharmacopsychiatry. 2001;34(3):91-95. [pmid: 11434405].
Murat Basar M, Tekdogan UY, Yilmaz E, et al. The efficacy of sildenafil in different etiologies of erectile dysfunction. International Urology & Nephrology. 2001;32(3):403-407. [pmid: 11583361].
Murphy AM, O'Leary M. Failure of the Ambicor inflatable penile prosthesis to deflate. Int J Impot Res. 2005;17(3):291-292. [pmid: 15605073].
Murphy JC, Srinivas S, Terris MK. Flutamide administration at 500 mg daily has similar effects on serum testosterone to 750 mg daily. J Androl. 2004;25(4):630-634. [pmid: 15223852].
Mydlo JH, Viterbo R, Crispen P. Use of combined intracorporal injection and a phosphodiesterase-5 inhibitor therapy for men with a suboptimal response to sildenafil and/or vardenafil monotherapy after radical retropubic prostatectomy. BJU Int. 2005;95(6):843-846. [pmid: 15794795].
Mydlo JH, Volpe MA, MacChia RJ. Results from different patient populations using combined therapy with alprostadil and sildenafil: predictors of satisfaction. BJU Int. 2000;86(4):469-473. [pmid: 10971274].
Nagai A, Kusumi N, Tsuboi H, et al. Intracavernous injection of prostaglandin E1 is effective in patients with erectile dysfunction not responding to phosphodiseterase 5 inhibitors. Acta Med Okayama. 2005;59(6):279-280. [pmid: 16418771].
Nalesnik JG, Jones L, Kraus SR. Group B streptococcal septicemia following intracavernous injection therapy for erectile dysfunction in diabetes. Br J Urol. 2004;172(1):151-152.
Nandipati K, Raina R, Agarwal A, et al. Early combination therapy: intracavernosal injections and sildenafil following radical prostatectomy increases sexual activity and the return of natural erections. Int J Impot Res. 2006;18(5):446-451. [pmid: 16482200].
Naude JH, Le Roux PJ. Topical treatment of erectile dysfunction did not show results.[comment]. BMJ. 1998;316(7140):1318. [pmid: 9554911].
Nehra A, Blute ML, Barrett DM, et al. Rationale for combination therapy of intraurethral prostaglandin E(1) and sildenafil in the salvage of erectile dysfunction patients desiring noninvasive therapy. Int J Impot Res. 2002;14(Suppl 1):38-42. [pmid: 11896476].
Nessel Mark A. Yohimbine and pentoxifylline in the treatment of erectile dysfunction. Am J Psychiatry. 1994;151(3):453.
Nurnberg H G, Hensley P L. Sildenafil citrate for the management of antidepressant-associated erectile dysfunction. Hillside J Clin Psychiatry 2003;64Suppl-5.
Nurnberg HG, Fava M, Gelenberg AJ, et al. Open-label sildenafil treatment of partial and non-responders to double-blind treatment in men with antidepressant-associated sexual dysfunction. Int J Impot Res. 2007;19(2):167-175. [pmid: 16871270].
Nurnberg HG, Gelenberg A, Hargreave TB, et al. Efficacy of sildenafil citrate for the treatment of erectile dysfunction in men taking serotonin reuptake inhibitors. Am J Psychiatry. 2001;158(11):1926-1928. [pmid: 11691705].
Nurnberg HG, Lauriello J, Hensley PL, et al. Sildenafil for iatrogenic serotonergic antidepressant medication-induced sexual dysfunction in 4 patients.[see comment]. Hillside J Clin Psychiatry. 1999;60(1):33-35.
Nurnberg HG, Seidman SN, Gelenberg AJ, et al. Depression, antidepressant therapies, and erectile dysfunction: clinical trials of sildenafil citrate (Viagra) in treated and untreated patients with depression. Urology. 2002;60(2 Suppl 2):58-66. [pmid: 12414334].
Nurnberg H, George Hensley, Paula L, et al. Sildenafil in the treatment of sexual dysfunction induced by selective serotonin reuptake inhibitors: An overview. [References]. CNS Drugs. 2000;13(5):321-335.
O'Sullivan JD, Hughes AJ. Apomorphine-induced penile erections in Parkinson's disease. Mov Disord. 1998;13(3):536-539. [pmid: 9613749].
Ochiai A, Naya Y, Soh J, et al. Efficacy of sildenafil as the first-step therapeutic tool for Japanese patients with erectile dysfunction. Int J Impot Res. 2005;17(4):339-342. [pmid: 15829991].
Ogura K, Ichioka K, Terada N, et al. Role of sildenafil citrate in treatment of erectile dysfunction after radical retropubic prostatectomy. Int J Urol. 2004;11(3):159-163. [pmid: 15009364].
Ohebshalom M, Mulhall JP. Transdermal and topical pharmacotherapy for male sexual dysfunction. Expert Opinion on Drug Delivery. 2005;2(1):115-120. [pmid: 16296739].
Ohebshalom M, Parker M, Guhring P, et al. The efficacy of sildenafil citrate following radiation therapy for prostate cancer: temporal considerations. Br J Urol. 2005;174(1):258-262.
Opsomer RJ, Wese FX, De Groote P, et al. The external vacuum device in the management of erectile dysfunction. Acta Urol Belg. 1997;65(4):13-16. [pmid: 9497591].
Ormrod D, Easthope SE, Figgitt DP. Vardenafil.[erratum appears in Drugs Aging 2002;19(11):886]. [Review] [30 refs]. Drugs Aging. 2002;19(3):217-227. [pmid: 12027779].
Osegbe D N, Shittu O B, Aghaji A E et al. Sildenafil citrate (Viagra) for the treatment of erectile dysfunction in Nigerian men. Int J Impot Res 2003;15Suppl-8.
Osterloh IH, Riley A. Clinical update on sildenafil citrate. [Review] [58 refs]. Br J Clin Pharmacol. 2002;53(3):219-223. [pmid: 11874383].
Osterloh I H, Collins M, Wicker P et al. Sildenafil citrate (VIAGRA): overall safety profile in 18 doubleblind, placebo controlled, clinical trials. [Review][0 refs]. Int J Clin Pract 1999;Supplement.102–105.
Padma-Nathan H, Yeager JL. An integrated analysis of alprostadil topical cream for the treatment of erectile dysfunction in 1732 patients. Urology. 2006;68(2):386-391. [pmid: 16904458].
Padma-Nathan H, Goldstein I, Klimberg I, et al. Long-term safety and efficacy of oral phentolamine mesylate (Vasomax) in men with mild to moderate erectile dysfunction. Int J Impot Res. 2002;14(4):266-270. [pmid: 12152116].
Padma-Nathan H, McMurray JG, Pullman WE, et al. On-demand IC351 (Cialis) enhances erectile function in patients with erectile dysfunction. Int J Impot Res. 2001;13(1):2-9. [pmid: 11313831].
Padma-Nathan H, Montorsi F, Giuliano F, et al. Vardenafil restores erectile function to normal range in men with erectile dysfunction. Br J Sex Med. 2007;4(1):152-161.
Pagani E, Glina S, Puech-Leao P, et al. Anxiety and high plasma catecholamines do not impair pharmaco-induced erection of psychogenic erectile dysfunctional patients. Int J Impot Res. 2003;15(4):282-286. [pmid: 12934057].
Pagani E, Puech-Leao P, Glina S, et al. The value of a second injection on the pharmaco-induced erection test. Int J Impot Res. 1997;9(3):167-168. [pmid: 9315495].
Pallas James, Levine Stephen B, Althof Stanley E, et al. A study using Viagra in a mental health practice. [References]. J Sex Marital Ther. 2000;26(1):41-50. [pmid: 10693115].
Palumbo F, Bettocchi C, Selvaggi FP, et al. Sildenafil: efficacy and safety in daily clinical experience. Eur Urol. 2001;40(2):176-180. [pmid: 11528195].
Pangkahila WI. Evaluation of transurethral application of alprostadil for erectile dysfunction in Indonesians. Asian J Androl. 2000;2(3):233-236. [pmid: 11225984].
Park K, Ku JH, Kim SW, et al. Risk factors in predicting a poor response to sildenafil citrate in elderly men with erectile dysfunction. BJU Int. 2005;95(3):366-370. [pmid: 15679795].
Parkerson George RJ, Willke Richard J, Hays Ron D. An international comparison of the reliability and responsiveness of the Duke Health Profile for measuring health-related quality of life of patients treated with alprostadil for erectile dysfunction. Med Care. 1999;37(1):56-67. [pmid: 10413393].
Penninga E, Jensen BA, Hansen PB, et al. Anagrelide treatment in 52 patients with chronic myeloproliferative diseases. Clinical & Laboratory Haematology. 2004;26(5):335-340. [pmid: 15485463].
Perimenis P, Athanasopoulos A, Geramoutsos I, et al. The incidence of pharmacologically induced priapism in the diagnostic and therapeutic management of 685 men with erectile dysfunction. Urol Int. 2001;66(1):27-29. [pmid: 11150947].
Perimenis P, Athanasopoulos A, Papathanasopoulos P, et al. Gabapentin in the management of the recurrent, refractory, idiopathic priapism. Int J Impot Res. 2004;16(1):84-85. [pmid: 14963477].
Perimenis P, Markou S, Gyftopoulos K, et al. Switching from long-term treatment with self-injections to oral sildenafil in diabetic patients with severe erectile dysfunction. Eur Urol. 2002;41(4):387-391. [pmid: 12074808].
Pescatori ES, Calpista A, Artibani W, et al. Self-injection devices for intracavernosal pharmacotherapy: operational classification and safety considerations. Int J Impot Res. 1996;8(2):53-57. [pmid: 8858390].
Peskircioglu L, Tekin MI, Demirag A, et al. Evaluation of erectile function in renal transplant recipients. Transplant Proc. 1998;30(3):747-749. [pmid: 9595082].
Peterson CA, Bennett AH, Hellstrom WJ, et al. Erectile response to transurethral alprostadil, prazosin and alprostadil-prazosin combinations. Br J Urol. 1998;159(5):1523-1527.
Petrov VI, Vekel'yan AS, Martyushev AV, et al. Impaza and Sildenafil: Comparison of Clinical Effectiveness in Patients with Erectile Dysfunction. Bull Exp Biol Med. 2003;135–136(Suppl 1):150-151.
Petty R, Angwin R. How real is the male menopause?. Br J Gen Pract. 2004;248(1659):452-456.
Pierce LJ, Whittington R, Hanno PM, et al. Pharmacologic erection with intracavernosal injection for men with sexual dysfunction following irradiation: a preliminary report. Int J Radiat Oncol Biol Phys. 1991;21(5):1311-1314. [pmid: 1938529].
Pohanka M, Kanovsky P, Bares M, et al. The long-lasting improvement of sexual dysfunction in patients with advanced, fluctuating Parkinson's disease induced by pergolide: evidence from the results of an open, prospective, one-year trial. Parkinsonism Relat Disord. 2005;11(8):509-512. [pmid: 15994112].
Pohanka M, Kanovsky P, Bares M, et al. Pergolide mesylate can improve sexual dysfunction in patients with Parkinson's disease: the results of an open, prospective, 6-month follow-up. Eur J Neurol. 2004;11(7):483-488. [pmid: 15257688].
Polak K, Wimpissinger B, Berisha F, et al. Effects of sildenafil on retinal blood flow and flicker-induced retinal vasodilatation in healthy subjects. Invest Ophthalmol Vis Sci. 2003;44(11):4872-4876. [pmid: 14578411].
Pomara G, Morelli G, Montorsi F, et al. Re: Montorsi F, Salonia A, Briganti A, Barbieri L, Zanni G, Surdi N, Cestari A, Montorsi P, Rigatti P. Vardenafil for the treatment of erectile dysfunction: A critical review of the literature based on personal clinical experience. Eur Urol 2005;47:612–21 (multiple letters). Eur Urol. 2005;48(2):345-346. [pmid: 15939526].
Pomara G, Morelli G, Pomara S, et al. Cardiovascular parameter changes in patients with erectile dysfunction using pde-5 inhibitors: a study with sildenafil and vardenafil. J Androl. 2004;25(4):625-629. [pmid: 15223851].
Pommerville P. Drug treatments for erectile dysfunction: An update. Geriatrics and Aging. 2004;7(6):10-16.
Porst H. IC351 (tadalafil, Cialis): update on clinical experience. [Review][12 refs]. Int J Impot Res 2002;14Suppl-64.
Porst H. Transurethral alprostadil with MUSE (medicated urethral system for erection) vs intracavernous alprostadil—a comparative study in 103 patients with erectile dysfunction. Int J Impot Res. 1997;9(4):187-192. [pmid: 9442415].
Porst H. Phosphodiesterase type-5 inhibitors: A critical comparative analysis. Eau Update Series. 2004;2(2):56-63.
Porst H, Lungimayr G, utsch-osterreichische STEA. [Efficacy and tolerability of vardenafil within the time window of 6 hours after administration and beyond. Results of a clinical study carried out in 233 urological offices]. MMW Fortschr Med. 2005;147(Suppl 1):27-32. [pmid: 16739369].
Potempa AJ, Ulbrich E, Bernard I, et al. Efficacy of vardenafil in men with erectile dysfunction: a flexible-dose community practice study. Eur Urol. 2004;46(1):73-79. [pmid: 15183550].
Pradeep C, Car N, Metelko Z. Impotence in diabetic men. Diabetol Croat. 1996;25(2):61-68.
Price D. Sildenafil citrate (Viagra) efficacy in the treatment of erectile dysfunction in patients with common concomitant conditions. Sildenafil Study Group. Int J Clin Pract 1999;Supplement.102–103.
Price DE, Cooksey G, Jehu D, et al. The management of impotence in diabetic men by vacuum tumescence therapy. Diabet Med. 1991;8(10):964-967. [pmid: 1838050].
Prieto Castro RM, nglada Curado FJ, Regueiro Lopez JC, et al. Treatment with sildenafil citrate in renal transplant patients with erectile dysfunction. BJU Int. 2001;88(3):241-243. [pmid: 11488737].
Priyadarshi S. Oral terbutaline in the management of pharmacologically induced prolonged erection. Int J Impot Res. 2004;16(5):424-426. [pmid: 14999218].
Pryor J. Vardenafil: update on clinical experience. [Review][10 refs]. Int J Impot Res 2002;14Suppl-9.
Purvis K, Brekke I, Christiansen E. Determinants of satisfactory rigidity after intracavernosal injection with prostaglandin E1 in men with erectile failure. Int J Impot Res. 1996;8(1):9-16. [pmid: 8735188].
Radomski SB, Herschorn S, Rangaswamy S. Topical minoxidil in the treatment of male erectile dysfunction. Br J Urol. 1994;151(5):1225-1226.
Raffaele R, Vecchio I, Giammusso B, et al. Efficacy and safety of fixed-dose oral sildenafil in the treatment of sexual dysfunction in depressed patients with idiopathic Parkinson's disease. Eur Urol. 2002;41(4):382-386. [pmid: 12074807].
Raina R, Agarwal A, Allamaneni SS, et al. Sildenafil citrate and vacuum constriction device combination enhances sexual satisfaction in erectile dysfunction after radical prostatectomy. Urology. 2005;65(2):360-364. [pmid: 15708053].
Raina R, Agarwal A, Goyal KK, et al. Long-term potency after iodine-125 radiotherapy for prostate cancer and role of sildenafil citrate. Urology. 2003;62(6):1103-1108. [pmid: 14665364].
Raina R, Lakin MM, Agarwal A, et al. Long-term intracavernous therapy responders can potentially switch to sildenafil citrate after radical prostatectomy. Urology. 2004;63(3):532-537. [pmid: 15028452].
Raina R, Lakin MM, Agarwal A, et al. Efficacy and factors associated with successful outcome of sildenafil citrate use for erectile dysfunction after radical prostatectomy. Urology. 2004;63(5):960-966. [pmid: 15134989].
Raina R, Lakin MM, Agarwal A, et al. Long-term effect of sildenafil citrate on erectile dysfunction after radical prostatectomy: 3-year follow-up. Urology. 2003;62(1):110-115. [pmid: 12837433].
Raina R, Lakin MM, Thukral M, et al. Long-term efficacy and compliance of intracorporeal (IC) injection for erectile dysfunction following radical prostatectomy: SHIM (IIEF-5) analysis. Int J Impot Res. 2003;15(5):318-322. [pmid: 14562131].
Rajpurkar A, Dhabuwala CB. Comparison of satisfaction rates and erectile function in patients treated with sildenafil, intracavernous prostaglandin E1 and penile implant surgery for erectile dysfunction in urology practice. Br J Urol. 2003;170(1):159-163.
Rakic Z, Starcevic V, Starcevic VP, et al. Testosterone treatment in men with erectile disorder and low levels of total testosterone in serum. Arch Sex Behav. 1997;26(5):495-504. [pmid: 9343635].
Ralph DJ, Sleep DJ, Perdok RJ, et al. Adverse events and patient tolerability of apomorphine SL 2 and 3 mg: A cross-study analysis of phase II and III studies. European Urology Supplements. 2002;1(3):21-27.
Ramasubbu Rajamannar. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Rashid A. The efficacy and safety of PDE5 inhibitors. [Review] [30 refs]. Clin Cornerstone. 2005;7(1):47-56. [pmid: 16156423].
Reiter WJ, Schatzl G, Mark I, et al. Dehydroepiandrosterone in the treatment of erectile dysfunction in patients with different organic etiologies. Urol Res. 2001;29(4):278-281. [pmid: 11585284].
Reznik I, Zemishlany Z, Kotler M, et al. Sildenafil citrate for the sexual dysfunction in antidepressant-treated male patients with posttraumatic stress disorder. A preliminary pilot open-label study. Psychotherapy & Psychosomatics. 2002;71(3):173-176. [pmid: 12021561].
Richardson JD. Intracorporeal injections for the treatment of impotence. Med J Aust. 1991;155(10):688. [pmid: 1943899].
Richter S, Vardi Y, Ringel A, et al. Intracavernous injections: still the gold standard for treatment of erectile dysfunction in elderly men. Int J Impot Res. 2001;13(3):172-175. [pmid: 11525316].
Rizvi K, Hampson JP, Harvey JN. Do lipid-lowering drugs cause erectile dysfunction? A systematic review.[see comment]. [Review] [35 refs]. Fam Pract. 2002;19(1):95-98. [pmid: 11818357].
Roach M, Winter K, Michalski JM, et al. Penile bulb dose and impotence after three-dimensional conformal radiotherapy for prostate cancer on RTOG 9406: findings from a prospective, multi-institutional, phase I/II dose-escalation study. Int J Radiat Oncol Biol Phys. 2004;60(5):1351-1356. [pmid: 15590164].
Robinson PK. An observational study of prostaglandin E-1: comparing trial and maintenance dose. Urol Nurs. 1994;14(3):76-78. [pmid: 7732420].
Rodilla F, Fuentes MD, Chuan P, et al. Penile self-injection for impotence in patients after radical cystectomy. Journal of Clinical Pharmacy & Therapeutics. 1994;19(6):359-360. [pmid: 7876367].
Rodrigues M, Granegger S, O'Grady J, et al. Accumulation of platelets as a key mechanism of human erection. A scintigraphic study in patients with erectile dysfunction receiving intracavernous injection of PGE1, papaverine/phentolamine. Advances in Experimental Medicine & Biology. 1997;43:379-82.
Rodrigues M, O'Grady J, Stackl W, et al. Accumulation of platelets as a key mechanism of human erection. Thromb Res. 1998;91(2):53-56. [pmid: 9722020].
Rodriguez Vela L, Lledo Garcia E, Rajmil O, et al. [Tadalafil vs sildenafil patient preference in Spanish men with erectile dysfunction: results from an International Multicentric Study]. Actas Urol Esp. 2006;30(1):67-79. [pmid: 16703733].
Rosas SE, Wasserstein A, Kobrin S, et al. Preliminary observations of sildenafil treatment for erectile dysfunction in dialysis patients. Am J Kidney Dis. 2001;37(1):134-137. [pmid: 11136178].
Rosas-Vargas H, Coral-Vazquez RM, Tapia R, et al. Glu298Asp endothelial nitric oxide synthase polymorphism is a risk factor for erectile dysfunction in the Mexican Mestizo population. J Androl. 2004;25(5):728-732. [pmid: 15292102].
Rosen RC, Shabsigh R, Kuritzky L, et al. The efficacy of tadalafil in improving sexual satisfaction and overall satisfaction in men with mild, moderate, and severe erectile dysfunction: A retrospective pooled analysis of data from randomized, placebo-controlled clinical trials. Current Medical Research & Opinion. 2005;21(11):1701-1709. [pmid: 16307689].
Rosen R, Janssen E, Wiegel M, et al. Psychological and interpersonal correlates in men with erectile dysfunction and their partners: a pilot study of treatment outcome with sildenafil. J Sex Marital Ther. 2006;32(3):215-234. [pmid: 16809250].
Rosenstock HA, Axelrad SD. Erectile dysfunction: on the efficacy of a phosphodiesterase inhibitor with concurrent sex therapy. Asian J Androl. 1999;1(4):207-210. [pmid: 11225896].
Rowland DL, Boedhoe HSM, Dohle G, et al. Intracavernosal self-injection therapy in men with erectile dysfunction: Satisfaction and attrition in 119 patients. Int J Impot Res. 1999;11(3):145-151. [pmid: 10404283].
Rowland DL, Myers L, Culver A, et al. Bupropion and sexual function: a placebo-controlled prospective study on diabetic men with erectile dysfunction. J Clin Psychopharmacol. 1997;17(5):350-357. [pmid: 9315985].
Rubio-Aurioles E, Porst H, Eardley I, et al. Comparing vardenafil and sildenafil in the treatment of men with erectile dysfunction and risk factors for cardiovascular disease: a randomized, double-blind, pooled crossover study. Br J Sex Med. 2006;3(6):1037-1049.
Rudkin L, Taylor M J, Hawton K. Strategies for managing sexual dysfunction induced by antidepressant medication. [Review][61 refs]. Cochrane Database Syst Rev 2004;(4):CD003382
Ruof J, Graf-Morgenstern M, Mnller MJ. Quality of life in patients with erection difficulties: Evaluation of a German version of the "Quality of life measure for men with erection difficulties" (QoL-Med). Aktuel Urol. 2001;32(1):21-26.
Saad F, Grahl AS, Aversa A, et al. Effects of testosterone on erectile function: implications for the therapy of erectile dysfunction. BJU Int. 2007;99(5):988-992. [pmid: 17309554].
Saad F, Hoesl CE, Oettel M, et al. Dehydroepiandrosterone treatment in the aging male - What should the urologist know?. Eur Urol. 2005;48(5):724-733. [pmid: 16137821].
Sadeghi-Nejad H, Lim H, Long K, et al. Assessment of the efficacy of Viagra (sildenafil citrate) using the Erectile Dysfunction Inventory of Treatment Satisfaction (EDITS). Urol Int. 2003;71(1):100-102. [pmid: 12845271].
Sadovsky R, Althof S. Men's sexual issues. Clinics in Family Practice. 2004;6(4 SPEC.ISS.):863-915.
Sahu MA, Ayyaz M, Chaudhry Z. Intracavernous injections of papaverine and phentolamine for treatment of impotence. J Coll Physicians Surg Pak. 1997;7(3):102-104.
Saie DJ, Sills ES. Hyperprolactinemia presenting with encephalomalacia-associated seizure disorder and infertility: A novel application for bromocriptine therapy in reproductive endocrinology. Neuroendocrinol Lett. 2005;26(5):533-537. [pmid: 16264405].
Salama N. Nocturnal electrobioimpedance volumetric assessment in diabetic men with erectile dysfunction before and after tadalafil intake. Int J Impot Res. 2004;16(5):441-447. [pmid: 15057255].
Salonia A, Rigatti P, Montorsi F. Sildenafil in erectile dysfunction: a critical review. Curr Med Res Opin. 2003;19(4):241-262. [pmid: 12841917].
Salonia Andrea, Briganti Alberto, Montorsi Piero, et al. Safety and tolerability of oral erectile dysfunction treatments in the elderly. [References]. Drugs and Aging. 2005;22(4):323-338. [pmid: 15839721].
Sato Y, Horita H, Adachi H, et al. Effect of oral administration of prostaglandin E1 on erectile dysfunction. Br J Urol. 1997;80(5):772-775. [pmid: 9393301].
Savoca G, Silvestre G, Belgrano E. Intracavernosal injection therapy and surgical therapy in diabetic patients with erectile dysfunction. [Review] [26 refs]. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):53-57.
Schanz S, Hauswirth U, Ulmer A, et al. Prostaglandin E(1) ethyl ester, a new agent for topical penile therapy. Int J Impot Res. 2002;14(4):317-318. [pmid: 12152124].
Schimmer AD, Ali V, Stewart AK, et al. Male sexual function after autologous blood or marrow transplantation. Biology of Blood & Marrow Transplantation. 2001;7(5):279-283. [pmid: 11400950].
Schmid DM, Schurch B, Hauri D. Sildenafil in the treatment of sexual dysfunction in spinal cord-injured male patients. Eur Urol. 2000;38(2):184-193. [pmid: 10895011].
Schouman M, Lacroix P, Amer M. Suppression of prostaglandin E1-induced pain by dilution of the drug with lidocaine before intracavernous injection. Br J Urol. 1992;148(4):1266.
Schroder FH, Whelan P, De Reijke TM, et al. Metastatic prostate cancer treated by flutamide versus cyproterone acetate. Final analysis of the "European Organization for Research and Treatment of Cancer" (EORTC) Protocol 30892. Eur Urol. 2004;45(4):457-464. [pmid: 15041109].
Schulman CC, Shen W, Stothard DR, et al. Integrated analysis examining first-dose success, success by dose, and maintenance of success among men taking tadalafil for erectile dysfunction. Urology. 2004;64(4):783-788. [pmid: 15491720].
Schultheiss D, Stief CG. Physiology and pathophysiology of erection: Consequences for present medical therapy of erectile dysfunction. Andrologia. 1999;31(SUPPL. 1):59-64. [pmid: 10643521].
Schultheiss D, Hiltl DM, Meschi MR, et al. Pilot study of the transdermal application of testosterone gel to the penile skin for the treatment of hypogonadotropic men with erectile dysfunction. World J Urol. 2000;18(6):431-435. [pmid: 11204264].
Seftel AD. From aspiration to achievement: Assessment and noninvasive treatment of erectile dysfunction in aging men. J Am Geriatr Soc. 2005;53(1):119-130. [pmid: 15667388].
Segraves RT, Lee J, Stevenson R, et al. Tadalafil for treatment of erectile dysfunction in men on antidepressants. J Clin Psychopharmacol. 2007;27(1):62-66. [pmid: 17224715].
Seidman SN, Pesce VC, Roose SP. High-dose sildenafil citrate for selective serotonin reuptake inhibitor-associated ejaculatory delay: open clinical trial. Hillside J Clin Psychiatry. 2003;64(6):721-725.
Setter SM, Iltz JL, Fincham JE, et al. Phosphodiesterase 5 inhibitors for erectile dysfunction. [Review] [75 refs]. Ann Pharmacother. 2005;39(78):1286-1295. [pmid: 15941818].
Sexton WJ, Benedict JF, Jarow JP. Comparison of long-term outcomes of penile prostheses and intracavernosal injection therapy.[see comment]. Br J Urol. 1998;159(3):811-815.
Shabbir M, Mikhailidis DM, Morgan RJ. Erectile dysfunction: an underdiagnosed condition associated with multiple risk factors.[comment]. Current Medical Research & Opinion. 2004;20(5):603-606. [pmid: 15140326].
Shabsigh R. Testosterone therapy in erectile dysfunction and hypogonadism. Br J Sex Med. 2005;2(6):785-792.
Shabsigh R. Hypogonadism and erectile dysfunction: The role for testosterone therapy. Int J Impot Res. 2003;15(SUPPL. 4):S9-S13. [pmid: 12934045].
Shabsigh R, Burnett AL, Eardley I, et al. Time from dosing to sexual intercourse attempts in men taking tadalafil in clinical trials. BJU Int. 2005;96(6):857-863. [pmid: 16153217].
Shabsigh R, Katz M, Yan G, et al. Cardiovascular issues in hypogonadism and testosterone therapy. [Review] [44 refs]. Am J Cardiol. 2005;96(12B):67M-72M. [pmid: 15979436].
Shabsigh R, Padma-Nathan H, Gittleman M, et al. Intracavernous alprostadil alfadex (EDEX/VIRIDAL) is effective and safe in patients with erectile dysfunction after failing sildenafil (Viagra). Urology. 2000;55(4):477-480. [pmid: 10736486].
Shamloul R. Management of honeymoon impotence. Br J Sex Med. 2006;3(2):361-366.
Shamloul R, Atteya A, Elnashaar A, et al. Intracavernous sodium nitroprusside (SNP) versus papaverine/phentolamine in erectile dysfunction: A comparative study of short- term efficacy and side- effects. Br J Sex Med. 2005;2(1):117-120.
Shamloul Rany, Kamel Ihab, et al. Early Treatment of Cavernositis Resulted in Erectile Function Preservation. [References]. Br J Sex Med. 2006;3(2):320-322.
Sharlip ID. Editorial comment. International Braz J Urol. 2005;31(4):354-355.
Sharlip I D. Can self-injection therapy cure impotence?. [Review] [7 refs]. Advances in Experimental Medicine & Biology. 1997;43:383-86.
Sharma RK, Prasad N, Kapoor R, et al. Treatment of erectile dysfunction with sidenafil citrate in renal transplant recipient: a cross over placebo controlled trial [abstract]. Indian Journal of Nephrology. 2002;12(4):23-238.
Shemtov OM, Radomski SB, Crook J. Success of sildenafil for erectile dysfunction in men treated with brachytherapy or external beam radiation for prostate cancer. Can J Urol. 2004;11(6):2450-2455. [pmid: 15636671].
Shenfeld OZ, Gofrit ON, Gdor Y, et al. The role of sildenafil in the treatment of erectile dysfunction in patients with pelvic fracture urethral disruption. Br J Urol. 2004;172(6 I):2350-2352.
Sheu JY, Chen KK, Lin AT, et al. Long-term efficacy and safety of sildenafil for patients with erectile dysfunction. Journal of the Chinese Medical Association: JCMA. 2003;66(8):480-486. [pmid: 14604312].
Shigemura K, Arakawa S, Kamidono S, et al. Effect of sildenafil on arterial stiffness, as assessed by pulse wave velocity, in patients with erectile dysfunction. Int J Urol. 2006;13(7):956-959. [pmid: 16882062].
Shimon I, Lubina A, Gorfine M, et al. Feedback inhibition of gonadotropins by testosterone in men with hypogonadotropic hypogonadism: comparison to the intact pituitary-testicular axis in primary hypogonadism. J Androl. 2006;27(3):358-364. [pmid: 16474013].
Shokeir AA, Alserafi MA, Mutabagani H. Intracavernosal versus intraurethral alprostadil: a prospective randomized study. BJU Int. 1999;83(7):812-815. [pmid: 10368203].
Siegel RL, Dubin NH, Andrade JR. Sildenafil citrate and sperm function [3] (multiple letters). American Journal of Obstetrics & Gynecology. 2001;184(4):777-778. [pmid: 11262489].
Sighinolfi MC, de Stefani S, Mofferdin A, et al. Intracavernous prostaglandin E1 infusion in diabetes with associated ischemic necrosis of the glans penis. Br J Urol. 2004;171(6 I):2380.
Silvestri A, Galetta P, Cerquetani E, et al. Report of erectile dysfunction after therapy with beta-blockers is related to patient knowledge of side effects and is reversed by placebo.[see comment]. Eur Heart J. 2003;24(21):1928-1932. [pmid: 14585251].
Singh AN, Scurlock H, Catalan J. Paroxetine induced erectile dysfunction successfully treated with yohimbine in patients suffering from HIV infection. Journal of Serotonin Research. 1995;1(4):283-285.
Slob AK, Verhulst ACM, Gijs L, et al. Intracavernous injection during diagnostic screening for erectile dysfunction: Five-year experience with over 600 patients. [References]. Br J Sex Med. 2002;28(1):61-70.
Smith KM, Romanelli F. Recreational use and misuse of phosphodiesterase 5 inhibitors. [Review] [56 refs]. Journal of the American Pharmacists Association: JAPhA. 2005;45(1):63-72. [pmid: 15730119].
Soh J, Naya Y, Ushijima S, et al. Efficacy of sildenafil for Japanese patients with audio-visual sexual stimulation (AVSS) test by the RigiScan Plus. Arch Androl. 2006;52(3):163-168. [pmid: 16574596].
Soler JM, Previnaire JG, Denys P, et al. Phosphodiesterase inhibitors in the treatment of erectile dysfunction in spinal cord-injured men. Proc Annu Clin Spinal Cord Inj Conf. 2007;45(2):169-173.
Sommer F, Engelmann U. Vardenafil: Bayer Yakuhin. Curr Opin Investig Drugs. 2002;3(4):607-613.
Sonksen J, Biering-Sorensen F. Transcutaneous nitroglycerin in the treatment of erectile dysfunction in spinal cord injured. Paraplegia. 1992;30(8):554-557. [pmid: 1522996].
Sparwasser C, Treiber U, Bahren W, et al. Postoperative erectile dysfunction; evaluation and treatment with intracavernous vasoactive injections. Progress in Clinical & Biological Research. 1991;370:349-354. [pmid: 1924468].
Speckens AE, Kattemolle MR, Hengeveld MW, et al. A prospective long-term follow-up study of patients evaluated for erectile dysfunction: outcome and associated factors. Int J Impot Res. 1995;7(2):101-110. [pmid: 7496438].
Speel TGW, Bleumer I, Diemont WL, et al. The value of sildenafil as mode of stimulation in pharmaco-penile duplex ultrasonography. Int J Impot Res. 2001;13(4):189-191. [pmid: 11494073].
Sperling H, Eisenhardt A, Virchow S, et al. Sildenafil response is influenced by the G protein beta 3 subunit GNB3 C825T polymorphism: a pilot study. Br J Urol. 2003;169(3):1048-1051.
Stanislavov R, Nikolova V. Treatment of erectile dysfunction with pycnogenol and L-arginine. J Sex Marital Ther. 2003;29(3):207-213. [pmid: 12851125].
Steers W, Guay AT, Leriche A, et al. Assessment of the efficacy and safety of Viagra (sildenafil citrate) in men with erectile dysfunction during long-term treatment. Int J Impot Res. 2001;13(5):261-267. [pmid: 11890512].
Steidle CP, McCullough AR, Kaminetsky JC, et al. Early sildenafil dose optimization and personalized instruction improves the frequency, flexibility, and success of sexual intercourse in men with erectile dysfunction. Int J Impot Res. 2007;19(2):154-160. [pmid: 16858367].
Stephenson RA, Mori M, Hsieh YC, et al. Treatment of erectile dysfunction following therapy for clinically localized prostate cancer: patient reported use and outcomes from the Surveillance, Epidemiology, and End Results Prostate Cancer Outcomes Study. Br J Urol. 2005;174(2):646-650.
Stief CG, Holmquist F, Djamilian M, et al. Preliminary results with the nitric oxide donor linsidomine chlorhydrate in the treatment of human erectile dysfunction. Br J Urol. 1992;148(5):1437-1440.
Stief CG, Uckert S, Jonas U. Strategies in the oral pharmacotherapy of male erectile dysfunction viewed from bench and bedside (Part II). The Journal of Mens Health & Gender. 2005;2(3):325-332.
Stief CG, Wetterauer U, Schaebsdau FH, et al. Calcitonin-gene-related peptide: a possible role in human penile erection and its therapeutic application in impotent patients. Br J Urol. 1991;146(4):1010-1014.
Stief C, Padley RJ, Perdok RJ, et al. Cross-study review of the clinical efficacy of apomorphine SL 2 and 3 mg: Pooled data from three placebo-controlled, fixed-dose crossover studies. European Urology Supplements. 2002;1(3):12-20.
Strahilevitz J, Rahav G, Schroers HJ, et al. An outbreak of Phialemonium infective endocarditis linked to intracavernous penile injections for the treatment of impotence. Clin Infect Dis. 2005;40(6):781-786. [pmid: 15736008].
Stroberg P, Murphy A, Costigan T. Switching patients with erectile dysfunction from sildenafil citrate to tadalafil: results of a European multicenter, open-label study of patient preference. Clin Ther. 2003;25(11):2724-2737. [pmid: 14693300].
Stuckey BGA. Tadalafil phase 3 experience. European Urology Supplements. 2002;1(8):25-30.
Swartz DA, Todd MW. Intracavernous papaverine and glaucoma.[see comment]. JAMA. 1990;264(5):570. [pmid: 2366292].
Tam PY, Keller T, Poppiti R, et al. Hemodynamic effects of transurethral alprostadil measured by color duplex ultrasonography in men with erectile dysfunction. Br J Urol. 1998;160(4):1321-1324.
Tam SW, Worcel M, Wyllie M. Yohimbine: a clinical review. [Review] [152 refs]. Pharmacol Ther. 2001;91(3):215-243. [pmid: 11744068].
Tanaka T. Papaverine hydrochloride in peripheral blood and the degree of penile erection. Br J Urol. 1990;143(6):1135-1137.
Tariq SH, Haleem U, Omran ML, et al. Erectile dysfunction: Etiology and treatment in young and old patients. Clin Geriatr Med. 2003;19(3):539-551. [pmid: 14567006].
Tas A, Ersoy A, Ersoy C, et al. Efficacy of sildenafil in male dialysis patients with erectile dysfunction unresponsive to erythropoietin and/or testosterone treatments. Int J Impot Res. 2006;18(1):61-68. [pmid: 16177828].
Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005;88(3):241-254. [pmid: 16162361].
Tekdogan U, Tuncel A, Tuglu D, et al. Effect of sildenafil citrate treatment on serum dehydroepiandrosterone sulfate levels in patients with erectile dysfunction. Urology. 2006;68(3):626-630. [pmid: 16979704].
Telias Isaac, Darwin Kadmon-Telias, Ana, et al. Four cases of erectile dysfunction in substance abusers treated with sildenafil. [References]. J Addict Dis. 2002;97(11):1473-1474.
Teloken C, Rhoden EL, Sogari P, et al. Therapeutic effects of high dose yohimbine hydrochloride on organic erectile dysfunction. Br J Urol. 1998;159(1):122-124.
Terradas C, Levalle O, Nagelberg A, et al. Sildenafil improves nocturnal penile erections in organic impotence. Int J Impot Res. 2001;13(2):125-129. [pmid: 11426352].
Tomlinson John M, Wright David, E-Mail Address et al. Impact of erectile dysfunction and its subsequent treatment with sildenafil: Qualitative study. [References]. BMJ: British Medical Journal 2004;328(7447):No
Tomsak R. PDE5 inhibitors and permanent visual loss. Int J Impot Res. 2005;17(6):547-549. [pmid: 16193072].
Tosti A, Pazzaglia M, Soli M, et al. Evaluation of sexual function with an international index of erectile function in subjects taking finasteride for androgenetic alopecia.[see comment]. Arch Dermatol. 2004;140(7):857-858. [pmid: 15262698].
Trinchieri A, Nicola M, Masini F, et al. Prospective comprehensive assessment of sexual function after retropubic non nerve sparing radical prostatectomy for localized prostate cancer. Arch Ital Urol Androl. 2005;77(4):219-223. [pmid: 16444937].
Truss MC, Becker AJ, Thon WF, et al. Intracavernous calcitonin gene-related peptide plus prostaglandin E1: possible alternative to penile implants in selected patients. Eur Urol. 1994;26(1):40-45. [pmid: 7925528].
Tsai YS, Lin JS, Lin YM. Safety and efficacy of alprostadil sterile powder (S. Po., CAVERJECT) in diabetic patients with erectile dysfunction. Eur Urol. 2000;38(2):177-183. [pmid: 10895010].
Tsujimura A, Yamanaka M, Takahashi T, et al. The clinical studies of sildenafil for the ageing male. Int J Androl. 2002;25(1):28-33. [pmid: 11869374].
Turk S, Karalezli G, Tonbul HZ, et al. Erectile dysfunction and the effects of sildenafil treatment in patients on haemodialysis and continuous ambulatory peritoneal dialysis. Nephrol.Dial.Transplant. 2001;16(9):1818-1822. [pmid: 11522864].
Turner LA, Althof SE. The clinical effectiveness of self-injection and external vacuum devices in the treatment of erectile dysfunction: a six-month comparison. Psychiatr Med. 1992;10(2):283-293. [pmid: 1377397].
Turner LA, Althof SE, Levine SB, et al. Twelve-month comparison of two treatments for erectile dysfunction: self-injection versus external vacuum devices. Urology. 1992;39(2):139-144. [pmid: 1736506].
Urciuoli R, Cantisani T A, CarliniI M et al. Prostaglandin E1 for treatment of erectile dysfunction. Cochrane Database Syst Rev 2004;(2):CD001784
Valicenti RK, Choi E, Chen C, et al. Sildenafil citrate effectively reverses sexual dysfunction induced by three-dimensional conformal radiation therapy. Urology. 2001;57(4):769-773. [pmid: 11306401].
Valiquette L, Montorsi F, Hellstrom WJ, et al. Penetration and maintenance of erection with vardenafil: a time-from-dosing analysis. Can J Urol. 2005;12(3):2687-2698. [pmid: 16011816].
van Basten JP, Van Driel MF, Jonker-Pool G, et al. Sexual functioning in testosterone-supplemented patients treated for bilateral testicular cancer. Br J Urol. 1997;79(3):461-467. [pmid: 9117232].
van Moorselaar RJ, Hartung R, Emberton M, et al. Alfuzosin 10 mg once daily improves sexual function in men with lower urinary tract symptoms and concomitant sexual dysfunction. BJU Int. 2005;95(4):603-608. [pmid: 15705088].
Van Ahlen H, Peskar BA, Sticht G, et al. Pharmacokinetics of vasoactive substances administered into the human corpus cavernosum. Br J Urol. 1994;151(5):1227-1230.
Van Dijk M, Skrekas T, De La, et al. The association between lower urinary tract symptoms and sexual dysfunction: Fact or fiction?. Curr Opin Urol. 2005;15(1):39-44. [pmid: 15586029].
Vardi M, Nini A. Phosphodiesterase inhibitors for erectile dysfunction in patients with diabetes mellitus. [Review][49 refs]. Cochrane Database Syst Rev 2007;(1):CD002187
Vardi Y, Sprecher E, Gruenwald I. Logistic regression and survival analysis of 450 impotent patients treated with injection therapy: long-term dropout parameters. Br J Urol. 2000;163(2):467-470.
Vickers MA, De Nobrega AM, Dluhy RG. Diagnosis and treatment of psychogenic erectile dysfunction in a urological setting: Outcomes of 18 consecutive patients. Br J Urol. 1993;149(5 SUPPL.):1258-1261.
Virag R. Indications and early results of sildenafil (Viagra) in erectile dysfunction. Urology. 1999;54(6):1073-1077. [pmid: 10604711].
Virag R. Intracavernous injection of papaverine for erectile failure. 1982. Br J Urol. 2002;167(2 Pt 2):1196.
Virag R, Floresco J, Richard C. Impairment of shear-stress-mediated vasodilation of cavernous arteries in erectile dysfunction. Int J Impot Res. 2004;16(1):39-42. [pmid: 14963469].
Vitezic D. A risk-benefit assessment of sildenafil in the treatment of erectile dysfunction. [Review] [72 refs]. Drug Saf. 2001;24(4):255-265. [pmid: 11330655].
von Heyden B, Donatucci CF, Kaula N, et al. Intracavernous pharmacotherapy for impotence: selection of appropriate agent and dose. [Review] [23 refs]. Br J Urol. 1993;149(5 Pt 2):1288-1290.
Wagner G, Montorsi F, Auerbach S, et al. Sildenafil citrate (VIAGRA) improves erectile function in elderly patients with erectile dysfunction: a subgroup analysis. J Gerontol A Biol.Sci Med Sci. 2001;56(2):M113-M119. [pmid: 11213274].
Wagrell L, Schelin S, Nordling J, et al. Three-year follow-up of feedback microwave thermotherapy versus TURP for clinical BPH: a prospective randomized multicenter study. Urology. 2004;64(4):698-702. [pmid: 15491704].
Wang CJ, Wu CC, Huang CH, et al. A comparative study with intracavernous injection of prostaglandin E1 versus papaverine for the diagnostic assessment of erectile impotence. Gaoxiong Yi Xue Ke Xue Za Zhi. 1992;8(11):585-590. [pmid: 1296038].
Wang ZL, Shao SX, Li B, et al. Sildenafil versus prostaglandin E1 in the management of erectile dysfunction. Journal of Clinical Urology. 2002;17(7):347-349.
Webb DJ, Freestone S, Allen MJ, et al. Sildenafil citrate and blood-pressure-lowering drugs: results of drug interaction studies with an organic nitrate and a calcium antagonist. Am J Cardiol. 1999;83(5A):21C-28C. [pmid: 10073779].
Weber DC, Bieri S, Kurtz JM, et al. Prospective pilot study of sildenafil for treatment of postradiotherapy erectile dysfunction in patients with prostate cancer. Am J Clin Oncol. 1999;17(11):3444-3449.
Weidner W, Schroeder-Printzen I, Fischer C, et al. Experience in the treatment of erectile dysfunction using the intracavernosal self-injection of papaverine: Results of a prospective study after a median follow-up of 42 months involving 135 patients and 10766 injections. World J Urol. 1992;10(3):179-182.
Weiss JN, Badlani GH, Ravalli R, et al. Reasons for high drop-out rate with self-injection therapy for impotence. Int J Impot Res. 1994;6(3):171-174. [pmid: 7735362].
Weiss JN, Ravalli R, Badlani GH. Intracavernous pharmacotherapy in psychogenic impotence. Urology. 1991;37(5):441-443. [pmid: 1708925].
Wen HS, Hsieh CH, Hsu GL, et al. The synergism of penile venous surgery and oral sildenafil in treating patients with erectile dysfunction.[see comment]. Int J Androl. 2005;28(5):297-303. [pmid: 16128990].
Werneke U, Crowe M. Review of patients with erectile dysfunction attending the Maudsley psychosexual clinic in 1999: The impact of sildenafil. Sexual & Relationship Therapy. 2002;17(2):171-185.
Werthman P, Rajfer J. MUSE therapy: preliminary clinical observations. Urology. 1997;50(5):809-811. [pmid: 9372900].
Wespes E, Rammal A, Garbar C. Sildenafil non-responders: haemodynamic and morphometric studies. Eur Urol. 2005;48(1):136-139. [pmid: 15967263].
Williams G. Male erectile dysfunction. Prescribers' Journal. 2000;40(1):49-58.
Williams G, Abbou CC, Amar ET, et al. The effect of transurethral alprostadil on the quality of life of men with erectile dysfunction, and their partners. MUSE Study Group. Br J Urol. 1998;82(6):847-854. [pmid: 9883223].
Williams T, Honeywell M, Branch E et al. Tadalafil in the treatment of erectile dysfunction. P & T 2004;29(5):
Willke RJ, Glick HA, McCarron TJ, et al. Quality of life effects of alprostadil therapy for erectile dysfunction. Br J Urol. 1997;157(6):2124-2128.
Wise Thomas N. Psychosocial side effects of sildenafil therapy for erectile dysfunction. J Sex Marital Ther. 1999;25(2):145-150. [pmid: 10327384].
Wolfson B, Pickett S, Scott NE, et al. Intraurethral prostaglandin E-2 cream: a possible alternative treatment for erectile dysfunction. Urology. 1993;42(1):73-75. [pmid: 8328127].
Wood P L. Slow, tedious but essential: The need for incremental R&D. Current Drug Discovery 2004;(pp 31–35):-35.
Wu CC, Xue ZY, Apichat K, et al. The use of alprostadil sterile powder in a home self-injection study of Asian men with erectile dysfunction. Clin Ther. 1996;18(2):256-264. [pmid: 8733986].
Wylie Kevan R, Hallam-Jones Ruth A, Steward David, et al. The combination of penoscrotal rings and PDE5i's in the treatment of erectile dysfunction - the Sheffield PDE5i and Ring Duo Technique. Two case reports. [References]. Sexual and Relationship Therapy. 2006;21(2):209-215.
Yaman O, Akand M, Gursoy A, et al. The effect of diabetes mellitus treatment and good glycemic control on the erectile function in men with diabetes mellitus-induced erectile dysfunction: a pilot study. Br J Sex Med. 2006;3(2):344-348.
Yaman O, Tokatli Z, Akand M, et al. Characteristics of sildenafil erections in healthy young men. Asian J Androl. 2005;7(4):395-398. [pmid: 16281087].
Yassin AA, Saad F. Improvement of sexual function in men with late-onset hypogonadism treated with testosterone only. Br J Sex Med. 2007;4(2):497-501.
Yassin AA, Saad F. Dramatic improvement of penile venous leakage upon testosterone administration. A case report and review of literature. Andrologia. 2006;38(1):34-37. [pmid: 16420241].
Yassin AA, Saad F, Traish A. Testosterone undecanoate restores erectile function in a subset of patients with venous leakage: a series of case reports. Br J Sex Med. 2006;3(4):727-735.
Yenicerioglu Y, Kefi A, Aslan G, et al. Efficacy and safety of sildenafil for treating erectile dysfunction in patients on dialysis. BJU Int. 2002;90(4):442-445. [pmid: 12175405].
Zaher TF. Papaverine plus prostaglandin E1 versus prostaglandin E1 alone for intracorporeal injection therapy. Int Urol Nephrol. 1998;30(2):193-196. [pmid: 9607891].
Zargooshi J. Unconsummated marriage: clarification of aetiology; treatment with intracorporeal injection. BJU Int. 2000;86(1):75-79. [pmid: 10886087].
Zasler ND. Therapeutic approaches to sexual impotence. Hospital Practice (Office Edition). 1988;23(7):197-200.
Zelefsky MJ, McKee AB, Lee H, et al. Efficacy of oral sildenafil in patients with erectile dysfunction after radiotherapy for carcinoma of the prostate. Urology. 1999;53(4):775-778. [pmid: 10197855].
Zesiewicz TA, Helal M, Hauser RA. Sildenafil citrate (Viagra) for the treatment of erectile dysfunction in men with Parkinson's disease. Mov Disord. 2000;15(2):305-308. [pmid: 10752581].
Zhang Y, Guan DL, Ou TW, et al. Sildenafil citrate treatment for erectile dysfunction after kidney transplantation. Transplant Proc. 2005;37(5):2100-2103. [pmid: 15964350].
Ziegler D. Management of erectile dysfunction in diabetic patients. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):58-65.
Zippe CD, Kedia AW, Kedia K, et al. Treatment of erectile dysfunction after radical prostatectomy with sildenafil citrate (Viagra). Urology. 1998;52(6):963-966. [pmid: 9836537].
Zippe CD, Kedia S, Kedia AW, et al. Sildenafil citrate (Viagra) after radical retropubic prostatectomy: pro. Urology. 1999;54(4):583-586. [pmid: 10510910].
Zlotta AR, Teillac P, Raynaud JP, et al. Evaluation of male sexual function in patients with Lower Urinary Tract Symptoms (LUTS) associated with Benign Prostatic Hyperplasia (BPH) treated with a phytotherapeutic agent (Permixon), Tamsulosin or Finasteride. Eur Urol. 2005;48(2):269-276. [pmid: 15939527].
Zorgniotti A. ‘“On demand” oral drug for erection in impotent men’. Br J Urol 1992;147308
Zorgniotti AW. Experience with buccal phentolamine mesylate for impotence. Int J Impot Res. 1994;6(1):37-41. [pmid: 7517275].
Zusman RM, Morales A, Glasser DB, et al. Overall cardiovascular profile of sildenafil citrate. [Review] [33 refs]. Am J Cardiol. 1999;83(5A):35C-44C.

## Not applicable

Annual update 2004/2005 - Treatment of genitourinary disorders. Drugs of the Future 2005;30(9):931–934.
Abrams J. Time course of the interaction between tadalafil and nitrates.[comment]. J Am Coll Cardiol. 2004;43(11):2150-2151. [pmid: 15172433].
Adaikan PG, Chong YS, Chew SSL, et al. Male sexual dysfunction. Curr Obstet Gynaecol. 2000;10(1):23-28.
Ahl J, Kinon B J, Liu-Seifert H. Sexual dysfunction associated with neuroleptic-induced hyperprolactinemia improves with reduction in prolactin levels. Ann N Y Acad Sci 2004;1032(pp 289–290):-290.
Ahuja SK, Krane NK, Hellstrom WJ. Penile prostheses in the management of impotence in patients with end-stage renal disease. J La State Med Soc. 1998;150(1):32-34. [pmid: 9448384].
Akbari F, Alavi M, Esteghamati A, et al. Effect of renal transplantation on sperm quality and sex hormone levels. BJU Int. 2003;92(3):281-283. [pmid: 12887484].
Akkus E, Kadioglu A, Esen A, et al. Prevalence and correlates of erectile dysfunction in Turkey: a population-based study. Eur Urol. 2002;41(3):298-304. [pmid: 12180232].
Alexandre B, Lemaire A, Desvaux P, et al. Intracavernous injections of prostaglandin E1 for erectile dysfunction: patient satisfaction and quality of sex life on long-term treatment. Br J Sex Med. 2007;4(2):426-431.
Alfonso A, Rieniets KI, Vigersky RA. Incidence and clinical significance of elevated macroprolactin levels in patients with hyperprolactinemia. Endocr Pract. 2006;12(3):275-280. [pmid: 16772199].
Alivizatos G, Skolarikos A, Laguna P. Recent data upon impotence, incontinence and quality of life issues concerning radical prostatectomy. [Review] [74 refs]. Arch Esp Urol. 2003;56(3):321-330. [pmid: 12768997].
Althof SE. Quality of life and erectile dysfunction. Urology. 2002;59(6):803-810. [pmid: 12031357].
Althof SE, Corty EW, Levine SB, et al. EDITS: development of questionnaires for evaluating satisfaction with treatments for erectile dysfunction. Urology. 1999;53(4):793-799. [pmid: 10197859].
Althof Stanley E, Turner Louisa A. Self-injection therapy and external vacuum devices in the treatment of erectile dysfunction: Methods and outcome. Rosen, Raymond C (Ed); Leiblum, Sandra Risa (Ed) 1992;(1992):378
Anderson RA, Bancroft J, Wu FC. The effects of exogenous testosterone on sexuality and mood of normal men. Journal of Clinical Endocrinology & Metabolism. 1992;75(6):1503-1507. [pmid: 1464655].
Anderson RA, Martin CW, Kung AW, et al. 7Alpha-methyl-19-nortestosterone maintains sexual behavior and mood in hypogonadal men. Journal of Clinical Endocrinology & Metabolism. 1999;84(10):3556-3562. [pmid: 10522995].
Anderson RA, Wallace AM, Sattar N, et al. Evidence for tissue selectivity of the synthetic androgen 7 alpha-methyl-19-nortestosterone in hypogonadal men. Journal of Clinical Endocrinology & Metabolism. 2003;88(6):2784-2793. [pmid: 12788888].
Andersson KE. Pharmacology of penile erection. Pharmacol Rev. 2001;53(3):417-450. [pmid: 11546836].
Andolsek KM. Alprostadil for the treatment of erectile dysfunction. Am Fam Physician. 1997;55(5):1902-1903.
Andriole G, Bruchovsky N, Chung LWK, et al. Dihydrotestosterone and the prostate: The scientific rationale for 5a-reductase inhibitors in the treatment of benign prostatic hyperplasia. Br J Urol. 2004;172(4 I):1399-1403.
Anonymous. Tadalafil: new preparation. Slightly more convenient, but poorly assessed in organic disorders. Prescrire Int 2003;12(68):213–215.
Anonymous. Tadalafil (cialis) for erectile dysfunction. Medical Letter on Drugs &Therapeutics 2003;45(1172):101–102.
Anonymous. First study of Viagra in black men demonstrates effective, well-tolerated treatment. Urol Nurs 2002;22(4):285–286.
Anonymous. Study shows patients taking vardenafil consistently completed sexual intercourse. Urol Nurs 2001;21(6):413–414.
Anonymous. Apomorphine (TAP holdings). 6a beta-aporphine-10,11-diol hydrochloride hemihydrate, apomorphine hydrochloride, spontane, Uprima. Drugs in R &D 1999;2(6):415–416.
Anonymous. Intraurethral alprostadil for impotence. Medical Letter on Drugs &Therapeutics 1997;39(997):32
Anonymous. Treatment for impotence gains FDA approval. Am J Health Syst Pharm 1995;52(19):2078–2079.
Anonymous. Intracavernous injection of alprostadil for erectile dysfunction. Medical Letter on Drugs &Therapeutics 1995;37(958):83–84.
Anonymous. Vardenafil works for 10 hours. Can Pharm J 2005;275(7360):133
Anonymous. Treatment duration of action is important in ED. Can Pharm J 2004;273(7330):878
Anonymous. Dutaseride. Prescrire Int 2004;13(73):183
Anonymous. Erratum: Efficacy and tolerability of sildenafil in Indian males with erectile dysfunction: A double-blind, randomized, placebo controlled, crossover study (Indian Journal of Pharmacology (2004) vol. 37 (5) (317)). Indian J Pharmacol 2004;36(6):391
Anonymous. Partnership struck between Bayer and Schering. Nat Rev Genet 2004;3(10):819
Anonymous. Erectile dysfunction drugs may reduce fertility but help depression. Can Pharm J 2004;272(7294):439
Anonymous. Sildenafil appears safe and effective for some heart failure patients. Can Pharm J 2004;272(7290):310
Anonymous. What to do when oral treatment fails?. Int J Impot Res 2003;15(SUPPL. 7):S30-S32.
Anonymous. Oral drug treatment of erectile dysfunction. Int J Impot Res 2003;15(SUPPL. 7):S27-S29.
Anonymous. Counselling and increased dose of sildenafil improves response in ED. British Journal of Diabetes &Vascular Disease 2003;3(6):445
Anonymous. Improve erectile function early after prostatectomy. Med Today 2003;4(11):8–9.
Anonymous. Recent FDA approval of new erectile dysfunction drug provides first challenge to sildenafil. Geriatrics and Aging 2003;6(8):11
Anonymous. New PDE 5 inhibitor efficacious for erectile dysfunction in diabetics. Cardiology Review 2003;20(10):
Anonymous. Inhaled apomorphine promising for erectile dysfunction treatment. Can Pharm J 2003;271(7261):170
Anonymous. Transurethral alprostadil. Prescrire Int 2002;11(61):144
Anonymous. IDdb News focus. Current Drug Discovery 2003;(pp 10–13):-13.
Anonymous. Sildenafil effective for sexual dysfunction associated with use of antidepressants. Can Pharm J 2003;270(7231):41
Anonymous. Vardenafil prolongs improved erectile function in diabetics. Cardiology Review 2002;19(10):38–39.
Anonymous. Erectile dysfunction treated effectively with tadalafil. Economics of Neuroscience 2001;3(11):19
Anonymous. New erectile dysfunction drug useful in diabetes. Can Pharm J 2001;267(7173):669
Anonymous. Erectile dysfunction - Alprostadil. Manuf Chem Aerosol News 2001;72(11):21
Anonymous. Erectile dysfunction - Vardenafil. Manuf Chem Aerosol News 2001;72(6):25
Anonymous. FDA approves oral therapy for erectile dysfunction. Am J Health Syst Pharm 1998;55(10):981–984.
Anonymous. Sildenafil Viagra(R) UK-92480: Treatment of erectile dysfunction phosphodiesterase V inhibitor. Drugs of the Future 1998;23(2):242–243.
Anonymous. Intracavernosal alprostadil for erectile dysfunction. Hospital Practice (Office Edition) 1996;31(8):136–137.
Anonymous. Intracavernous alprostadil: Effective therapy for erectile dysfunction. Drugs &Therapy Perspectives 1996;7(6):1–5.
Anonymous. Heart drug with ‘viagra side-effect’. Indian J Med Sci 1999;53(5):236
Anonymous. What to do if Viagra won't do. Harvard Mens Health Watch 2005;9(10):4–8.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: intracavernous injection of prostaglandin E1. JAMA 1991;265(24):3321–3323.
Anonymous. Diagnostic and therapeutic technology assessment. Vasoactive intracavernous pharmacotherapy for impotence: papaverine and phentolamine. JAMA 1990;264(6):752–754.
Ansong KS, Punwaney RB. An assessment of the clinical relevance of serum testosterone level determination in the evaluation of men with low sexual drive. Br J Urol. 1999;162(3 I):719-721.
Ansong KS, Lewis C, Jenkins P, et al. Epidemiology of erectile dysfunction: a community-based study in rural New York State. Ann Epidemiol. 2000;10(5):293-296. [pmid: 10942877].
Arafa M, Eid H, Shamloul R. Significance of phentolamine redosing during prostaglandin E1 penile color Doppler ultrasonography in diagnosis of vascular erectile dysfunction. Int J Urol. 2007;14(5):476-477. [pmid: 17511742].
Araujo AB, O'Donnell AB, Brambilla DJ, et al. Prevalence and incidence of androgen deficiency in middle-aged and older men: Estimates from the Massachusetts male aging study. Journal of Clinical Endocrinology & Metabolism. 2004;89(12):5920-5926. [pmid: 15579737].
Araujo Andre B, Durante Richard, Feldman Henry A, et al. The relationship between depressive symptoms and male erectile dysfunction: Cross-sectional results from the Massachusetts male aging study. Psychosom Med. 1998;60(4):458-465. [pmid: 9710291].
Arnavaz A, Aurich A, Weissenborn K, et al. Effect of sildenafil (Viagra) on cerebral blood flow velocity: a pilot study. Psychiatry Res. 2003;122(3):207-209. [pmid: 12694895].
Arnold R, Beer D, Bhalay G, et al. 8-Aryl xanthines potent inhibitors of phosphodiesterase 5. Bioorg Med Chem Lett. 2002;12(18):2587-2590. [pmid: 12182866].
Aronson JK. Features of this month's Journal. Br J Clin Pharmacol. 2003;55(4):327-328.
Arslan D, Esen AA, Secil M, et al. A new method for the evaluation of erectile dysfunction: sildenafil plus Doppler ultrasonography. Br J Urol. 2001;166(1):181-184.
Arthur R. Cardiovascular disorders and erectile dysfunction. British Journal of Cardiology. 2002;9(3):144-145.
Ashton AK, Jamerson BD, Weinstein WL, et al. Antidepressant-related adverse effects impacting treatment compliance: Results of a patient survey. Current Therapeutic Research, Clinical & Experimental. 2005;66(2):96-106.
Atala A. What's new in urology. J Am Coll Surg. 2004;199(3):446-461. [pmid: 15325616].
Atikeler MK, Gecit I, Senol FA. Optimum usage of prilocaine-lidocaine cream in premature ejaculation. Andrologia. 2002;34(6):356-359. [pmid: 12472618].
Atmaca M, Kuloglu M, Tezcan E. A new atypical antipsychotic: quetiapine-induced sexual dysfunctions. Int J Impot Res. 2005;17(2):201-203. [pmid: 15284834].
Avasthi A, Basu D, Kulhara P, et al. Psychosexual dysfunction in Indian male patients: Revisited after seven years. Arch Sex Behav. 1994;23(6):685-695. [pmid: 7872862].
Aversa A, Mazzilli F, Rossi T, et al. Effects of sildenafil (Viagra) administration on seminal parameters and post-ejaculatory refractory time in normal males. Hum Reprod. 2000;15(1):131-134. [pmid: 10611201].
Aydin S, Unal D, Erol H, et al. Multicentral clinical evaluation of the aetiology of erectile dysfunction: a survey report. International Urology & Nephrology. 2001;32(4):699-703. [pmid: 11989568].
Ayub W, Fletcher S. End-stage renal disease and erectile dysfunction. Is there any hope?. Nephrology Dialysis Transplantation. 2000;15(10):1525-1528.
Bagatell CJ, Heiman JR, Rivier JE, et al. Effects of endogenous testosterone and estradiol on sexual behavior in normal young men.[erratum appears in J Clin Endocrinol Metab 1994 Jun;78(6):1520]. Journal of Clinical Endocrinology & Metabolism. 1994;78(3):711-716. [pmid: 8126146].
Baggaley MR, Hirst JF, Watson JP. Outcome of patients referred to a psychosexual clinic with erectile failure. Sexual & Marital Therapy. 1996;11(2):123-130.
Bai WJ, Zhu JC, Jiang H, et al. [A comparative study of different vasoactive drugs in the treatment of impotence]. Chinese Journal of Urology. 1992;13(6):453-455.
Bailey J, Evans JP, Hardy M, et al. Synopsis: 2005 Annual Meeting of the American Society of Andrology. J Androl. 2005;26(6):678-688. [pmid: 16291961].
Bancroft J, Munoz M, Beard M, et al. The effects of a new alpha-2 adrenoceptor antagonist on sleep and nocturnal penile tumescence in normal male volunteers and men with erectile dysfunction. Psychosom Med. 1995;57(4):345-356. [pmid: 7480564].
Baniel J, Israilov S, Segenreich E, et al. Comparative evaluation of treatments for erectile dysfunction in patients with prostate cancer after radical retropubic prostatectomy. BJU Int. 2001;88(1):58-62. [pmid: 11446847].
Barnas J, Parker M, Guhring P, et al. The utility of tamsulosin in the management of orgasm-associated pain: a pilot analysis.[see comment]. Eur Urol. 2005;47(3):361-365. [pmid: 15716202].
Barqawi A, O'Donnell C, Kumar R, et al. Correlation between LUTS (AUA-SS) and erectile dysfunction (SHIM) in an age-matched racially diverse male population: data from the Prostate Cancer Awareness Week (PCAW). Int J Impot Res. 2005;17(4):370-374. [pmid: 15889121].
Bartlik Barbara D, Kaplan Peter, Kaplan Helen S. Psychostimulants apparently reverse sexual dysfunction secondary to selective serotonin re-uptake inhibitors. J Sex Marital Ther. 1995;21(4):264-271. [pmid: 8789508].
Bayes M, Rabasseda X, Prous JR. Gateways to Clinical Trials. Methods & Findings in Experimental & Clinical Pharmacology. 2004;26(9):723-753. [pmid: 15632957].
bdel-Khalek M, El-Hammady S, Ibrahiem el. A 4-year follow-up of a randomized prospective study comparing transurethral electrovaporization of the prostate with neodymium: YAG laser therapy for treating benign prostatic hyperplasia. BJU Int. 2003;91(9):801-805. [pmid: 12780836].
Beard S, Hunn A, Wight J. Treatments for spasticity and pain in multiple sclerosis: A systematic review. Health Technol Assess. 2003;7(40):111p.
Beasley CM, Mitchell MI, Dmitrienko AA, et al. The combined use of ibutilide as an active control with intensive electrocardiographic sampling and signal averaging as a sensitive method to assess the effects of tadalafil on the human QT interval.[see comment]. J Am Coll Cardiol. 2005;46(4):678-687. [pmid: 16098435].
Becher E, Glina S. Erectile dysfunction in Latin America and treatment with sildenafil citrate (Viagra): Introduction. Int J Impot Res. 2002;14(SUPPL. 2):S1-S2. [pmid: 12161761].
Bella AJ, Brock GB. Tadalafil: A comprehensive update. Journal of Drug Evaluation. 2004;2(8):225-246.
Benson GS. The clinical evaluation of the patient presenting with erectile dysfunction: what is reasonable?. [Review] [27 refs]. Semin Urol. 1990;8(2):94-99. [pmid: 2191404].
Beretta G, Saltarelli O, Marzotto M, et al. Transcutaneous minoxidil in the treatment of erectile dysfunctions in spinal cord injured men. Acta Eur Fertil. 1993;24(1):27-30. [pmid: 8303971].
Bestane WJ, Bestane MC, Ramos NA. Prospective study of sodium nitroprusside in pharmacologically induced erection. Braz J Urol. 2001;27(2):155-158.
Beutel ME, Wiltink J, Hauck EW, et al. Correlations between hormones, physical, and affective parameters in aging urologic outpatients. Eur Urol. 2005;47(6):749-755. [pmid: 15925068].
Bhatia MS, Malik SC. Dhat syndrome—a useful diagnostic entity in Indian culture. Br J Psychiatry. 1991;159(Nov.):691-695. [pmid: 1756347].
Bivalacqua TJ, Hellstrom WJG. Potential application of gene therapy for the treatment of erectile dysfunction. J Androl. 2001;22(2):183-190. [pmid: 11229791].
Black AM, Day AG, Morales A. The reliability of clinical and biochemical assessment in symptomatic late-onset hypogonadism: Can a case be made for a 3-month therapeutic trial?. BJU Int. 2004;94(7):1066-1070. [pmid: 15541129].
Blander DS, Sanchez-Ortiz RF, Broderick GA. Sex inventories: can questionnaires replace erectile dysfunction testing?. Urology. 1999;54(4):719-723. [pmid: 10510935].
Boccon Gibod L. Is transurethral needle ablation a safe and effective treatment for lower urinary tract symptoms secondary to BPH?. Nature Clinical Practice Urology. 2004;1(1):24-25.
Bochinski DJ, Dean RC, Lue TF. Erectile dysfunction and priapism. Nat Clin Pract Urol. 2004;1(1):49-53. [pmid: 16474467].
Bodie JA, Beeman WW, Monga M. Psychogenic erectile dysfunction. Int J Psychiatry Med. 2003;33(3):273-293. [pmid: 15089008].
Bodie J, Lewis J, Schow D, et al. Laboratory evaluations of erectile dysfunction: an evidence based approach. Br J Urol. 2003;169(6):2262-2264.
Bodner DR, Leffler B, Frost F. The role of intracavernous injection of vasoactive medications for the restoration of erection in spinal cord injured males: a three year follow up. Paraplegia. 1992;30(2):118-120. [pmid: 1589286].
Boolell M, Allen MJ, Ballard SA, et al. Sildenafil: an orally active type 5 cyclic GMP-specific phosphodiesterase inhibitor for the treatment of penile erectile dysfunction. Int J Impot Res. 1996;8(2):47-52. [pmid: 8858389].
Boshier A, Wilton LV, Shakir SAW. Evaluation of the safety of sildenafil for male erectile dysfunction: Experience gained in general practice use in England in 1999. BJU Int. 2004;93(6):796-801. [pmid: 15049992].
Boydak B, Nalbantgil S, Fici F, et al. A randomised comparison of the effects of nebivolol and atenolol with and without chlorthalidone on the sexual function of hypertensive men. Clinical Drug Investigation. 2005;25(6):409-416. [pmid: 17532681].
Brake M, Loertzer H, Horsch R, et al. Treatment of Peyronie's disease with local interferon-alpha 2b. BJU Int. 2001;87(7):654-657. [pmid: 11350406].
Bratus D, Hlebic G, Hajdinjak T. 16905960 of erectile dysfunction. Croat Med J. 2007;48(1):76-80. [pmid: 17309142].
Brennemann W, Kohler W, Zierz S, et al. Testicular dysfunction in adrenomyeloneuropathy. Eur J Endocrinol. 1997;137(1):34-39. [pmid: 9242199].
Brennemann W, Stitz B, Van Ahlen H, et al. Treatment of idiopathic erectile dysfunction in men with the opiate antagonist naltrexone—a double-blind study. J Androl. 1993;14(6):407-410. [pmid: 8294223].
Briganti A, Chun FKH, Salonia A, et al. A comparative review of apomorphine formulations for erectile dysfunction: Recommendations for use in the elderly. Drugs Aging. 2006;23(4):309-319. [pmid: 16732690].
Briganti A, Salonia A, Zanni G, et al. Erectile dysfunction and radical prostatectomy: An update. Eau Update Series. 2004;2(2):84-92.
Brixius K, Middeke M, Lichtenthal A, et al. Nitric oxide, erectile dysfunction and beta-blocker treatment (MR NOED study): Benefit of nebivolol versus metoprolol in hypertensive men. Clinical & Experimental Pharmacology & Physiology. 2007;34(4):327-331. [pmid: 17324145].
Broderick GA, Allen G, McClure RD. Vacuum tumescence devices: the role of papaverine in the selection of patients. Br J Urol. 1991;145(2):284-286.
Brooks DP, Giuliano F. Genitourinary diseases. Drug Discovery Today: Therapeutic Strategies. 2005;2(1):iii-iiv.
Brown JS, Wessells H, Chancellor MB, et al. Urologic complications of diabetes. Diabetes Care. 2005;28(1):177-185. [pmid: 15616253].
Buchholz NP, Weuste R, Mattarelli G, et al. Post-vasectomy erectile dysfunction. J Psychosom Res. 1994;38(7):759-762. [pmid: 7877130].
Buddeberg C, Bucher T, Hornung R. [Erectile dysfunction in men in their second half of life]. Urologe 2005;Ausg. A. 44(9):1045–1046, 1048–51.
Buena F, Swerdloff RS, Steiner BS, et al. Sexual function does not change when serum testosterone levels are pharmacologically varied within the normal male range. Fertility & Sterility. 1993;59(5):1118-1123. [pmid: 8486184].
Bukofzer S, Livesey N. Safety and tolerability of apomorphine SL (Uprima). Int J Impot Res. 2001;13(SUPPL. 3):S40-S44. [pmid: 11477491].
Burnett AL. Efficacy of tadalafil for the treatment of erectile dysfunction at 24 and 36 hours after dosing: A randomized controlled trial: Editorial comment 2. Urology. 2003;62(1):126.
Burnett AL. Vasoactive pharmacotherapy to cure erectile dysfunction: fact or fiction?. [Review] [45 refs]. Urology. 2005;65(2):224-230. [pmid: 15708027].
Burnett AL. The impact of sildenafil on molecular science and sexual health. Eur Urol. 2004;46(1):9-14. [pmid: 15183543].
Burns-Cox N, Gingell C. The andropause: fact or fiction?. [Review] [49 refs]. Postgrad Med J. 1997;73(863):553-556. [pmid: 9373594].
Buvat J, Boujadoue G. Testosterone replacement therapy in the ageing man. The Journal of Mens Health & Gender. 2005;2(4):396-399.
Calof OM, Singh AB, Lee ML, et al. Adverse events associated with testosterone replacement in middle-aged and older men: A meta-analysis of randomized, placebo-controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60(11):1451-1457.
Campbell M. Beneficial cardiovascular effects and safety of sildenafil reported in trio of studies. Cardiology Review. 2001;18(6):27.
Cappelleri JC, Siegel RL, Glasser DB, et al. Relationship between patient self-assessment of erectile dysfunction and the sexual health inventory for men. Clin Ther. 2001;23(10):1707-1719. [pmid: 11726005].
Cara AM, Lopes-Martins RAB, Antunes E, et al. The role of histamine in human penile erection. Br J Urol. 1995;75(2):220-224. [pmid: 7850330].
Carani C, Bancroft J, Granata A, et al. Testosterone and erectile function, nocturnal penile tumescence and rigidity, and erectile response to visual erotic stimuli in hypogonadal and eugonadal men. Psychoneuroendocrinology. 1992;17(6):647-654. [pmid: 1287683].
Carani C, Scuteri A, Marrama P, et al. The effects of testosterone administration and visual erotic stimuli on nocturnal penile tumescence in normal men. Horm Behav. 1990;24(3):435-441. [pmid: 2227854].
Cardenas DD, Ditunno J, Graziani V, et al. Phase 2 trial of sustained-release fampridine in chronic spinal cord injury. Proc Annu Clin Spinal Cord Inj Conf. 2007;45(2):158-168.
Carey Michael P, Wincze John P, Meisler Andrew W. Sexual dysfunction: Male erectile disorder. Barlow, David H (Ed) 1993;(1993):534
Carosa E, Benvenga S, Trimarchi F, et al. Sexual inactivity results in reversible reduction of LH bioavailability. Int J Impot Res. 2002;14(2):93-99. [pmid: 11979323].
Carson CC. PNU-83757: a new agent for the treatment of erectile dysfunction.[comment]. Curr Urol Rep. 2002;3(6):465-466. [pmid: 12425868].
Carson CC. Re: Long-term efficacy of sildenafil and tachyphylaxis effect.[comment]. Br J Urol. 2002;168(1):205.
Carson CC, Hatzichristou DG, Carrier S. Erratum: Erectile response with vardenafil in sildenafil nonresponders: A multicentre, double-blind, 12-week, flexible-dose, placebo-controlled erectile dysfunction clinical trial (BJU International (2004) 94 (1301–1309)). BJU Int. 2005;96(3):466.
Caspi A, Goldenberg M M. Sildenafil: A new drug treatment for male erectile dysfunction. P & T 1998;23(5):
Cawello W, Schweer H, Dietrich B, et al. Pharmacokinetics of prostaglandin E1 and its main metabolites after intracavernous injection and short-term infusion of prostaglandin E1 in patients with erectile dysfunction. Br J Urol. 1997;158(4):1403-1407.
Cecchi M, Sepich CA, Felipetto R, et al. Vacuum constriction device and topical minoxidil for management of impotence. Arch Esp Urol. 1995;48(10):1058-1059. [pmid: 8588728].
Chaiban JT, Azar ST. Erectile dysfunction in diabetic patients. J Med Liban. 2004;52(4):217-219. [pmid: 16432985].
Chang DW, Wood CG, Kroll SS, et al. Cavernous nerve reconstruction to preserve erectile function following non-nerve-sparing radical retropubic prostatectomy: a prospective study. Keisei Geka. 2003;111(3):1174-1181.
Chatterjee R, Andrews HO, McGarrigle HH, et al. Cavernosal arterial insufficiency is a major component of erectile dysfunction in some recipients of high-dose chemotherapy/chemoradiotherapy for haematological malignancies. Bone Marrow Transplant. 2000;25(11):1185-1189. [pmid: 10849531].
Chaudhuri TK, Fink S, Burger RH, et al. Nuclear penogram: Non-invasive technique to monitor and record effect of pharmacologically-induced penile erection in impotence therapy. Urology. 1990;35(1):98. [pmid: 2296828].
Chen CT, Valicenti RK, Lu J, et al. Does hormonal therapy influence sexual function in men receiving 3D conformal radiation therapy for prostate cancer?. Int J Radiat Oncol Biol Phys. 2001;50(3):591-595. [pmid: 11395224].
Chen J, Greenstein A, Kaver I, et al. Use of automatic insulin injector for intracorporeal injection in erectile dysfunction. Br J Urol. 1994;152(2):461-462.
Chen J, Mabjeesh NJ, Greenstein A. Sildenafil versus the vacuum erection device: patient preference. Br J Urol. 2001;166(5):1779-1781.
Chen J, Wollman Y, Chernichovsky T, et al. Effect of oral administration of high-dose nitric oxide donor L-arginine in men with organic erectile dysfunction: results of a double-blind, randomized, placebo-controlled study. BJU Int. 1999;83(3):269-273. [pmid: 10233492].
Chen KC, Minor TX, Rahman NU, et al. The additive erectile recovery effect of brain-derived neurotrophic factor combined with vascular endothelial growth factor in a rat model of neurogenic impotence. BJU Int. 2005;95(7):1077-1080. [pmid: 15839936].
Chen KK, Jiann BP, Lin JSN, et al. Erratum: Efficacy and safety of on- demand oral tadalafil in the treatment of men eith erectile dysfunction in Taiwan: A randomized, double- blind, parallel, placebo- conrolled clinical study (Journal of Sexual Medicine vol. 1 (2)). Br J Sex Med. 2005;2(1):158.
Cheng JYW, Ng EML, Chen RYL, et al. Prevalence of erectile dysfunction in Asian populations: A meta-analysis. Int J Impot Res. 2007;19(3):229-244. [pmid: 16929338].
Chew KK, Stuckey BG. Clinical course of penile fibrosis in intracavernosal prostaglandin E1 injection therapy: a follow-up of 44 patients. Int J Impot Res. 2003;15(2):94-98. [pmid: 12789387].
Chew KK, Stuckey BGA, Thompson PL. Erectile dysfunction, sildenafil and cardiovascular risk. Med J Aust. 2000;172(6):279-283. [pmid: 10860094].
Chia S. Management of premature ejaculation—a comparison of treatment outcome in patients with and without erectile dysfunction. Int J Androl. 2002;25(5):301-305. [pmid: 12270028].
Chinegwundoh F, Anie K A. Treatments for priapism in boys and men with sickle cell disease. [Review][16 refs]. Cochrane Database Syst Rev 2004;(4):CD004198
Chiu KC, Cohan P, Martinez D, et al. Adrenal insufficiency after medical therapy for prolactin and adrenocorticotropic hormone co-producing pituitary macroadenoma without hypercortisolism. Endocr Pract. 2001;11(6):443-446.
Chiu YJ, Reid IA. Effect of sildenafil on renin secretion in human subjects. Experimental biology and medicine (Maywood, NJ). 2002;227(8):620-625.
Christ B, Brockmeier D, Hauck EW, et al. Interactions of sildenafil and tacrolimus in men with erectile dysfunction after kidney transplantation. Urology. 2001;58(4):589-593. [pmid: 11597545].
Christ GJ, Melman A. The application of gene therapy to the treatment of erectile dysfunction. Int J Impot Res. 1998;10(2):111-112. [pmid: 9647947].
Chue P. Gabapentin treatment for premature ejaculation [3]. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 2004;49(9):644-645. [pmid: 15503740].
Cimentepe E, Unsal A, Saglam R. Randomized clinical trial comparing transurethral needle ablation with transurethral resection of the prostate for the treatment of benign prostatic hyperplasia: results at 18 months. J Endourol. 2003;17(2):103-107. [pmid: 12689404].
Clark C. Erectile dysfunction and other problems. Can Pharm J. 2004;272(7299):608-610.
Clark RV, Hermann DJ, Cunningham GR, et al. Marked Suppression of Dihydrotestosterone in Men with Benign Prostatic Hyperplasia by Dutasteride, a Dual 5a-Reductase Inhibitor. Journal of Clinical Endocrinology & Metabolism. 2004;89(5):2179-2184. [pmid: 15126539].
Claro JA, Passerotti CC, Figueiredo Neto AC, et al. An alternative non-invasive treatment for Peyronie's disease. International Braz J Urol. 2004;30(3):199-204. [pmid: 15689246].
Clough J. CNS-targeted sexual dysfunction drug for men and women. Drug Discov Today. 2002;7(9):492-494. [pmid: 11983559].
Coelho OR. Tolerability and safety profile of sildenafil citrate (Viagra) in Latin American patient populations. Int J Impot Res. 2002;14(Suppl 2):54-59. [pmid: 11896479].
Coker C, Bettocchi C, Pryor J. Caverject, a new licensed prostaglandin preparation for use in erectile dysfunction. J Androl. 1994;15(6 SUPPL.):71S.
Coleman CI, Carabino JM, Vergara CM, et al. Vardenafil. Hosp Formul. 2003;38(3):131-148.
Collazos J, Martinez E, Mayo J, et al. Sexual dysfunction in HIV-infected patients treated with highly active antiretroviral therapy. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2002;31(3):322-326. [pmid: 12439208].
Colp GM, Scroppo FI. Can self-directed pelvic floor exercises improve erectile function?. Nature Clinical Practice Urology. 2005;2(3):128-129.
Conti CR, Pepine CJ, Sweeney M. Efficacy and safety of sildenafil citrate in the treatment of erectile dysfunction in patients with ischemic heart disease. Am J Cardiol. 1999;83(5A):29C-34C.
Contreras LN, Masini AM, Danna MM, et al. Glucocorticoids: their role on gonadal function and LH secretion. Minerva Endocrinol. 1996;21(2):43-46. [pmid: 8968148].
Cooper AJ, Losztyn S, Russell NC, et al. Medroxyprogesterone acetate, nocturnal penile tumescence, laboratory arousal, and sexual acting out in a male with schizophrenia. Arch Sex Behav. 1990;19(4):361-372. [pmid: 2144727].
Cormio L, Nisen H, Ruutu M, et al. Etilefrine in the prevention of prolonged erection after diagnostic pharmacological stimulation. Ann Chir Gynaecol. 1996;85(3):247-250. [pmid: 8950448].
Corona G, Mannucci E, Petrone L, et al. ANDROTEST: a structured interview for the screening of hypogonadism in patients with sexual dysfunction. Br J Sex Med. 2006;3(4):706-715.
Corona G, Mannucci E, Petrone L, et al. Association of hypogonadism and type II diabetes in men attending an outpatient erectile dysfunction clinic. Int J Impot Res. 2006;18(2):190-197. [pmid: 16136189].
Corona G, Mannucci E, Schulman C, et al. Psychobiologic correlates of the metabolic syndrome and associated sexual dysfunction. Eur Urol. 2006;50(3):595-604. [pmid: 16564129].
Creasey GH. Lecture 6: restoration of male sexual function following spinal cord injury. Int J Impot Res. 2000;12(Suppl 3):S54-S55. [pmid: 11002403].
Crum-Cianflone NF, Bavaro M, Hale B, et al. Erectile dysfunction and hypogonadism among men with HIV. AIDS Patient Care & Stds. 2007;21(1):9-19. [pmid: 17263654].
Culha M, Mutlu N, Acar O, et al. Patient-partner satisfaction with intracavernous medication supported with oral agents in selected cases of Peyronie's disease: A ten-month follow-up study. International Urology & Nephrology. 1999;31(2):257-262. [pmid: 10481972].
Curri SB, Menchini Fabris F. Evidence and results obtained with a new Trans-Epidermal Barrier (T.E.B.) drug in the medical treatment of vascular impotence. Boll Chim Farm. 1996;135(5):316-334. [pmid: 8942060].
Cyranoski D. Malaysian researchers bet big on home-grown Viagra. Nat Med. 2005;11(9):912. [pmid: 16145563].
Czuriga I, Riecansky I, Bodnar J, et al. Comparison of the New Cardioselective Beta-Blocker Nebivolol with Bisoprolol in Hypertension: The Nebivolol, Bisoprolol Multicenter Study (NEBIS). Cardiovascular Drugs & Therapy. 2003;17(3):257-263. [pmid: 14574084].
Dang G, Matern R, Bivalacqua TJ, et al. Intralesional interferon-alpha-2B injections for the treatment of Peyronie's disease. South Med J. 2004;97(1):42-46. [pmid: 14746421].
Davis BE, Weigel JW, Whitford CS. Treatment of male impotence: a new option. Kans Med. 1990;91(12):325-326. [pmid: 1705298].
Davis JM. American College of Neuropsychopharmacology - 43rd annual meeting. 12–16 December 2004, San Juan, Puerto Rico. IDrugs. 2005;8(2):100-103. [pmid: 15696406].
Davis ME, Brewster ME. Cyclodextrin-based pharmaceutics: Past, present and future. Nat Rev Genet. 2004;3(12):1023-1035.
De Meyer JM, Oosterlinck W. Influence of the method of intracavernous injection on penile rigidity: a possible pharmacokinetic explanation. Urology. 1997;49(2):248-252. [pmid: 9037289].
De Rosa M, Zarrilli S, Vitale G, et al. Six months of treatment with cabergoline restores sexual potency in hyperprolactinemic males: an open longitudinal study monitoring nocturnal penile tumescence. Journal of Clinical Endocrinology & Metabolism. 2004;89(2):621-625. [pmid: 14764772].
De Tejada I. Vardenafil Duration of Action. Eur Urol. 2006;50(5):901-902. [pmid: 16949729].
De Tejada I, Garvey DS, Schroeder JD, et al. Design and evaluation of nitrosylated alpha-adrenergic receptor antagonists as potential agents for the treatment of impotence. Journal of Pharmacology & Experimental Therapeutics. 1999;290(1):121-128. [pmid: 10381767].
Degirmenci B, Acar M, Albayrak R, et al. Effects of sildenafil citrate (Viagra) on renal arteries: An evaluation with Doppler ultrasound. Urol Int. 2006;77(2):170-172. [pmid: 16888425].
Del Popolo G, Li Marzi V, Mondaini N, et al. Time/duration effectiveness of sildenafil versus tadalafil in the treatment of erectile dysfunction in male spinal cord-injured patients. Proc Annu Clin Spinal Cord Inj Conf. 2004;42(11):643-648.
Delizonna LL, Wincze JP, Litz BT, et al. A comparison of subjective and physiological measures of mechanically produced and erotically produced erections (or, is an erection an erection?). J Sex Marital Ther. 2001;27(1):21-31. [pmid: 11224951].
Denisov MF, Davis JM, Brecher M. Re: Prolactin levels and adverse events in patients treated with risperidone [8] (multiple letters). J Clin Psychopharmacol. 2002;22(5):538-540. [pmid: 12352286].
Derby CA, Araujo AB, Johannes CB, et al. Measurement of erectile dysfunction in population-based studies: the use of a single question self-assessment in the Massachusetts Male Aging Study. Int J Impot Res. 2000;12(4):197-204. [pmid: 11079360].
Derby CA, Barbour MM, Hume AL, et al. Drug therapy and prevalence of erectile dysfunction in the Massachusetts Male Aging Study cohort. Pharmacotherapy. 2001;21(6):676-683. [pmid: 11401181].
Derouet H, Nolden W, Jost WH, et al. Treatment of erectile dysfunction by an external ischiocavernous muscle stimulator. Eur Urol. 1998;34(4):355-359. [pmid: 9748685].
Desouza C, Parulkar A, Lumpkin D, et al. Acute and prolonged effects of sildenafil on brachial artery flow-mediated dilatation in type 2 diabetes. Diabetes Care. 2002;25(8):1336-1339. [pmid: 12145231].
Dietzen CJ, Lloyd LK. Complications of intracavernous injections and penile prostheses in spinal cord injured men. Archives of Physical Medicine & Rehabilitation. 1992;73(7):652-655. [pmid: 1622321].
Dinelli N, Salinitri G, Pomara G, et al. Role of pharmacologic rehabilitation in the recovery of sexual function following radical prostatectomy. Minerva Urol Nefrol. 2005;57(4):325-329. [pmid: 16247354].
Dinsmore WW, Gingell C, Hackett G, et al. Treating men with predominantly nonpsychogenic erectile dysfunction with intracavernosal vasoactive intestinal polypeptide and phentolamine mesylate in a novel auto-injector system: a multicentre double-blind placebo-controlled study. BJU Int. 1999;83(3):274-279. [pmid: 10233493].
Djavan B, Milani S, Fong YK. Dutasteride: A novel dual inhibitor of 5a-reductase for benign prostatic hyperplasia. Expert Opin Pharmacother. 2005;6(2):311-317. [pmid: 15757426].
Donatucci CF, Lue TF. Erectile dysfunction in men under 40: etiology and treatment choice. Int J Impot Res. 1993;5(2):97-103. [pmid: 8348217].
Doumas M, Tsakiris A, Douma S, et al. Beneficial effects of switching from beta-blockers to nebivolol on the erectile function of hypertensive patients. Asian J Androl. 2006;8(2):177-182. [pmid: 16491268].
Dundar SO. Visual loss associated with erectile dysfunction drugs. Can J Ophthalmol. 2007;42(1):10-12. [pmid: 17361234].
Dupont Simon. Multiple sclerosis and sexual functioning: A review. Clin Rehabil. 1995;9(2):135-141.
Durackova Z, Trebaticky B, Novotny V, et al. Lipid metabolism and erectile function improvement by Pycnogenol, extract from the bark of Pinus pinaster in patients suffering from erectile dysfunction - A pilot study. Adv Food Nutr Res. 2003;23(9):1189-1198.
Eandi J A, Yao A P, Javidan J. Penile paraffinoma: the delayed presentation. Int Urol Nephrol 2007;
Eardley I. New oral therapies for the treatment of erectile dysfunction. Br J Urol. 1998;81(1):122-127. [pmid: 9467488].
Earle CM, Keogh EJ, Ker JK, et al. The role of intracavernosal vasoactive agents to overcome impotence due to spinal cord injury. Paraplegia. 1992;30(4):273-276. [pmid: 1625897].
Earle CM, Stuckey BG, Ching HL, et al. The incidence and management of priapism in Western Australia: a 16 year audit. Int J Impot Res. 2003;15(4):272-276. [pmid: 12934055].
Edwards G, Muirhead GJ. British Journal of Clinical Pharmacology: Introduction. Br J Clin Pharmacol. 2002;53(SUPPL. 1):1S-3S.
Ekmekcioglu O, Inci M, Demirci D, et al. Effects of sildenafil citrate on ejaculation latency, detumescence time, and refractory period: placebo-controlled, double-blind, crossover laboratory setting study. Urology. 2005;65(2):347-352. [pmid: 15708051].
Ekselius L, Von Knorring L. Effect on sexual function of long-term treatment with selective serotonin reuptake inhibitors in depressed patients treated in primary care. J Clin Psychopharmacol. 2001;21(2):154-160. [pmid: 11270911].
El-Bahnasawy MS, El-Assmy A, Dawood A, et al. Effect of the use of internal iliac artery for renal transplantation on penile vascularity and erectile function: A prospective study. Br J Urol. 2004;172(6 I):2335-2339.
El-Rufaie Omer EF, Bener Abdulbari, Abuzeid Mohamed SO, et al. Sexual dysfunction among type II diabetic men: A controlled study. J Psychosom Res. 1997;43(6):605-612. [pmid: 9430073].
El-Sakka AI. Penile axial rigidity and Doppler ultrasonography parameters in patients with erectile dysfunction: association with type 2 diabetes. Urology. 2003;62(3):525-531. [pmid: 12946761].
Emilien G. Alprox-TD NexMed Inc. Current Opinion in Central & Peripheral Nervous System Investigational Drugs. 2000;2(3):311-320.
Ende AR, Lo Re V, DiNubile MJ, et al. Erectile dysfunction in an urban HIV-positive population. AIDS Patient Care & Stds. 2006;20(2):75-78. [pmid: 16475887].
Engelson ES, Pi-Sunyer FX, Kotler DP. Effects of megestrol acetate therapy on body composition and circulating testosterone concentrations in patients with AIDS. Int J STD AIDS. 1995;9(9):1107-1108.
Engl T, Beecken WD, Wolfram M, et al. Uropharmacology: Current and future strategies in the treatment of erectile dysfunction and benign prostate hyperplasia. International Journal of Clinical Pharmacology & Therapeutics. 2004;42(10):527-533. [pmid: 15516021].
Ensign C. First-line therapies for erectile dysfunction. [Review] [8 refs]. JAAPA. 2001;14(10):17-20. [pmid: 11715672].
Erdogru T, Kocak T, Serdaroglu P, et al. Evaluation and therapeutic approaches of voiding and erectile dysfunction in neurological Behcet's syndrome. Br J Urol. 1999;162(1):147-153.
Ernst E. Chinese herbal medicines for consumers in the West. Focus on Alternative & Complementary Therapies. 2005;10(2):94-97.
Esposito K, Giugliano F, Martedi E, et al. High proportions of erectile dysfunction in men with the metabolic syndrome. Diabetes Care. 2005;28(5):1201-1203. [pmid: 15855589].
Evans MF. Viagra! Are we ready?. Can Fam Physician. 1998;44:2103-2105. [pmid: 9805164].
Fagan Peter J, Blum Lois H. Issues in the psychotherapeutic treatment of sexual dysfunction following radical retropubic prostatectomy. Rosen, Raymond C (Ed); Leiblum, Sandra R (Ed) 1995;(1995):400
Fagan TC, Buttler S, Marbury T, et al. Cardiovascular safety of sublingual apomorphine in patients on stable doses of oral antihypertensive agents and nitrates. Am J Cardiol. 2001;88(7):760-766. [pmid: 11589843].
Faiman C. Endocrine causes of impotence. Cleve Clin J Med. 1993;60(6):428-429. [pmid: 7507006].
Fedele D, Lamonica M, Bax G. Experience with sildenafil in diabetes. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):49-52.
Fekete F, Fabian E. [Effectiveness and adverse effects of sildenafil in erectile dysfunction]. Orv Hetil. 2000;141(3):115-118. [pmid: 10693332].
Feldman HA, Goldstein I, Hatzichristou DG, et al. Impotence and its medical and psychosocial correlates: results of the Massachusetts Male Aging Study. Br J Urol. 1994;151(1):54-61.
Feldman HA, Johannes CB, Derby CA, et al. Erectile dysfunction and coronary risk factors: prospective results from the Massachusetts male aging study. Prev Med. 2000;30(4):328-338. [pmid: 10731462].
Finkbeiner A. Random musing about a little blue pill. J Ark Med Soc. 1998;95(3):100-101. [pmid: 9735630].
Fisher WA, Rosen RC, Eardley I, et al. The Multinational Men's Attitudes to Life Events and Sexuality (MALES) Study Phase II: Understanding PDE5 inhibitor treatment seeking patterns, among men with erectile dysfunction. Br J Sex Med. 2004;1(2):150-160.
Flack JM. The effect of doxazosin on sexual function in patients with benign prostatic hyperplasia, hypertension, or both.[see comment]. [Review] [47 refs]. Int J Clin Pract. 2002;56(7):527-530. [pmid: 12296615].
Foresta C, Caretta N, Rossato M, et al. Role of androgens in erectile function. Br J Urol. 2004;171(6 Pt 1):2358-2362.
Frank T. Tadalafil (Cialis-Lilly). Consultant Pharmacist. 2004;19(4):280-281.
Frank T. Vardenafil (Levitra-Bayer) GSK. Consultant Pharmacist. 2004;19(4):278-280.
Franzen D, Metha A, Seifert N, et al. Effects of beta-blockers on sexual performance in men with coronary heart disease. A prospective, randomized and double blinded study. Int J Impot Res. 2001;13(6):348-351. [pmid: 11918251].
Fraunfelder F W, Fraunfelder F T. Scientific Challenges in Postmarketing Surveillance of Ocular Adverse Drug Reactions. Am J Ophthalmol 2007;143(1):
Freemantle N. Valuing the effects of sildenafil in erectile dysfunction. Br Med J. 2000;320(7243):1156-1157. [pmid: 10784525].
Freytag SO, Stricker H, Pegg J, et al. Phase I Study of Replication-Competent Adenovirus-Mediated Double-Suicide Gene Therapy in Combination with Conventional-Dose Three-Dimensional Conformal Radiation Therapy for the Treatment of Newly Diagnosed, Intermediate- to High-Risk Prostate Cancer. Cancer Res. 2003;63(21):7497-7506. [pmid: 14612551].
Fu Q, Yao DH, Jiang YQ. Effect of sodium nitroprusside on hemodynamics of corpus cavernosum in Chinese. Asian J Androl. 2001;3(4):311-313. [pmid: 11753478].
Fulgram PF, Cochran JS, Denman JL, et al. Re: Disappointing initial results with transurethral alprostadil for erectile dysfunction in a urology practice setting [5]. Br J Urol. 1999;162(4):1390.
Gallo L, Perdona S, Autorino R, et al. Recovery of erection after pelvic urologic surgery: our experience. Int J Impot Res. 2005;17(6):484-493. [pmid: 15889123].
Gerstenbluth RE, Maniam PN, Corty EW, et al. Prostate-specific antigen changes in hypogonadal men treated with testosterone replacement. J Androl. 2002;23(6):922-926. [pmid: 12399540].
Ghezzi A, Malvestiti GM, Baldini S, et al. Erectile impotence in multiple sclerosis: A neurophysiological study. J Neurol. 1995;242(3):123-126. [pmid: 7751853].
Giammusso B, Gattuso U, Vanaclocha V, et al. Percutaneous lumbar sympathectomy in the treatment of erectile dysfunction secondary to cavernous adrenergic hypertone: initial results of an original technique. Arch Ital Urol Androl. 2005;77(1):5-9. [pmid: 15906781].
Giampietro O, Ferdeghini M, Cerri M, et al. Evaluation of the hypothalamic-pituitary-testicular interaction in diabetic males. European J Lab Med. 1994;2(2):83-89.
Ginsberg DL. Gabapentin treatment of premature ejaculation. Primary Psychiatry. 2004;11(12):20-21.
Ginsberg DL. Vardenafil treatment of sertraline-induced sexual dysfunction. Primary Psychiatry. 2004;11(11):23-24.
Giuberti A, Picozzi SC, Mazza L, et al. Testosterone supplementation in hypogonadal men: our personal experience. Arch Ital Urol Androl. 2005;77(4):191-193. [pmid: 16444930].
Giuliano F. Control of penile erection by the melanocortinergic system: Experimental evidences and therapeutic perspectives. J Androl. 2004;25(5):683-691. [pmid: 15292097].
Giuliano F, Allard J, Rampin O, et al. Pro-erectile effect of systemic apomorphine: Existence of a spinal site of action. Br J Urol. 2002;167(1):402-406.
Giuliano F, Hultling C, El Masry WS, et al. Randomized trial of sildenafil for the treatment of erectile dysfunction in spinal cord injury. Sildenafil Study Group. Ann Neurol. 1999;46(1):15-21. [pmid: 10401776].
Giuliano Francois, Pena Beatrice, Mishra Avanish, et al. "Efficacy results and quality-of-life measures in men receiving sildenafil citrate for the treatment of erectile dysfunction": Erratum. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care & Rehabilitation. 2002;11(6):613-670.
Gladh YM, Rahgozar M, Hammar ML, et al. Prevalence of symptoms possibly related to PADAM, in a Swedish population aged 55, 65 and 75 years. Maturitas. 2005;50(3):161-166. [pmid: 15734596].
Glasser SP. Revisiting erectile dysfunction in cardiovascular patients. Cardiology Review. 2003;20(12):42-43.
Glasser SP. Safety of PDE 5 inhibition in patients with cardiovascular disease. Cardiology Review. 2002;19(11):32-33.
Glenn DRJ, McClure N, Lewis SEM. The hidden impact of diabetes on male sexual dysfunction and fertility. Hum Fertil. 2003;6(4):174-179.
Gontero P, Fontana F, Zitella A, et al. A prospective evaluation of efficacy and compliance with a multistep treatment approach for erectile dysfunction in patients after non-nerve sparing radical prostatectomy. BJU Int. 2005;95(3):359-365. [pmid: 15679794].
Govier FE, McClure RD, Kramer-Levien D. Endocrine screening for sexual dysfunction using free testosterone determinations. Br J Urol. 1996;156(2 Pt 1):405-408.
Graul A, Castaner J. Phentolamine Mesilate. Treatment of erectile dysfunction. Drugs of the Future. 1998;23(7):725-728.
Graul AI. Latest findings on the diagnosis and treatment of erectile dysfunction. Drug News Perspect. 1996;9(9):572-575.
Gray PB, Singh AB, Woodhouse LJ, et al. Dose-dependent effects of testosterone on sexual function, mood, and visuospatial cognition in older men. Journal of Clinical Endocrinology & Metabolism. 2005;90(7):3838-3846. [pmid: 15827094].
Green HJ, Pakenham KI, Headley BC, et al. Coping and health-related quality of life in men with prostate cancer randomly assigned to hormonal medication or close monitoring. Psychooncology. 2002;11(5):401-414. [pmid: 12228873].
Green JSA, Holden STR, Ingram P, et al. An investigation of erectile dysfunction in Gwent, Wales. BJU Int. 2001;88(6):551-553. [pmid: 11678749].
Greenstein A, Plymate SR, Katz PG. Visually stimulated erection in castrated men. Br J Urol. 1995;153(3:Pt 1):t-2.
Gresser U, Gleiter CH. Erectile dysfunction: comparison of efficacy and side effects of the PDE-5 inhibitors sildenafil, vardenafil and tadalafil—review of the literature. [Review] [92 refs]. Eur J Med Res. 2002;7(10):435-446. [pmid: 12435622].
Gross AJ, Sauerwein DH, Kutzenberger J, et al. Penile prostheses in paraplegic men. Br J Urol. 1996;78(2):262-264. [pmid: 8813925].
Grugni G, Carani C, Maestroni G, et al. Melatonin levels in psychogenic impotence. Hormone & Metabolic Research. 1994;26(9):440-441. [pmid: 7835831].
Grunwald JE, Jacob SS, Siu K, et al. Acute effects of sildenafil citrate (Viagra) on intraocular pressure in open-angle glaucoma. Am J Ophthalmol. 2001;132(6):872-874. [pmid: 11730651].
Gryglewska B, Grodzicki T. Betaxolol in elderly patients in primary care. New Medicine. 2003;6(4):108-111.
Guay AT, Sabharwal P, Varma S, et al. Delayed diagnosis of psychological erectile dysfunction because of the presence of macroprolactinemia. Journal of Clinical Endocrinology & Metabolism. 1996;81(7):2512-2514. [pmid: 8675569].
Guay DRP. Geriatric pharmacotherapy updates. American Journal Geriatric Pharmacotherapy. 2004;2(1):81-87.
Guirguis W R, Maytom M C, Orr M et al. SILDENAFIL FOR ERECTILE DYSFUNCTION - A ONE-YEAR STUDY. 151st Annual Meeting of the American Psychiatric Association 1998;Toronto, Ontario, Canada. 30th May-4th June. 1998. Issue No. 63, 1998.
Guo YL, Zhu JC, Pan TM, et al. Efficacy and safety of oral sildenafil in the treatment of erectile dysfunction. Chinese Journal of Urology. 2001;22(7):389-394.
Gupta S, Salimpour P, Saenz de, et al. A possible mechanism for alteration of human erectile function by digoxin: inhibition of corpus cavernosum sodium/potassium adenosine triphosphatase activity. Br J Urol. 1998;159(5):1529-1536.
Hackett GI. The treatment of patients with diabetes. Int J STD AIDS. 1996;7(Suppl 3):24-26. [pmid: 8876378].
Haensel SM, Klem TM, Hop WC, et al. Fluoxetine and premature ejaculation: a double-blind, crossover, placebo-controlled study. J Clin Psychopharmacol. 1998;18(1):72-77. [pmid: 9472846].
Haensel SM, Rowland DL, Kallan KT. Clomipramine and sexual function in men with premature ejaculation and controls. Br J Urol. 1996;156(4):1310-1315.
Hamed S, Mohamed K, El-taher A, et al. The sexual and reproductive health in men with generalized epilepsy: A multidisciplinary evaluation. Int J Impot Res. 2006;18(3):287-295. [pmid: 16254569].
Hammadeh MY, Philp T. Transurethral electrovaporization of the prostate (TUVP) is effective, safe and durable. [Review] [28 refs]. Prostate Cancer & Prostatic Diseases. 2003;6(2):121-126. [pmid: 12806369].
Hanash KA. Comparative results of goal oriented therapy for erectile dysfunction. Br J Urol. 1997;157(6):2135-2138.
Harman SM. Testosterone, Sexuality, and Erectile Function in Aging Men. J Androl. 2003;24(6 SUPPL.):S42-S45. [pmid: 14581494].
Hartmann Uwe, Langer Dieter. Combination of psychosexual therapy and intrapenile injections in the treatment of erectile dysfunctions: Rationale and predictors of outcome. J Sex Educ Ther. 1993;19(1):1-12.
Harwood PJ, Grotz M, Eardley I, et al. Erectile dysfunction after fracture of the pelvis. Journal of Bone & Joint Surgery - British Volume. 2005;87(3):281-290.
Haslam MT. A trial of idazoxan and yohimbine in erectile dysfunction. Sex Marital Ther. 1992;7(3):261-266.
Hatzimouratidis K, Hatzichristou D. Testosterone and erectile function: an unresolved enigma. Eur Urol. 2007;52(1):26-28. [pmid: 17379397].
Hawton Keith, Catalan Jose, Fagg Joan. Sex therapy for erectile dysfunction: Characteristics of couples, treatment outcome, and prognostic factors. Arch Sex Behav. 1992;21(2):161-175. [pmid: 1580787].
Hazell P. Review of new compounds available in Australia for the treatment of attention-deficit hyperactivity disorder. Australasian Psychiatry. 2004;12(4):369-375. [pmid: 15715810].
Heaton J. New classification system for erectile dysfunction therapies. J Androl. 1998;19(4):399-404. [pmid: 9733141].
Heaton JPW, Altwein JE. The role of apomorphine SL in the treatment of male erectile dysfunction. BJU International - Supplement. 2001;88(3):36-38.
Heaton JP, Dean J, Sleep DJ. Sequential administration enhances the effect of apomorphine SL in men with erectile dysfunction. Int J Impot Res. 2002;14(1):61-64. [pmid: 11896482].
Hellstrom WJG, Kendirci M. Type 5 Phosphodiesterase Inhibitors: Curing Erectile Dysfunction. Eur Urol. 2006;49(6):942-945. [pmid: 16563607].
Hellstrom WJ, Overstreet JW, Yu A, et al. Tadalafil has no detrimental effect on human spermatogenesis or reproductive hormones.[see comment]. Br J Urol. 2003;170(3):887-891.
Hellstrom Wayne JG, Egan Robert A, McGee Hall T, et al. "Visual field defect and intracerebral hemorrhage associated with use of vardenafil (Levitra)": Comment and Reply. [References]. Neurology. 2006;66(2):293-294. [pmid: 16434684].
Herrmann HC, Chang G, Klugherz BD, et al. Hemodynamic effects of sildenafil in men with severe coronary artery disease.[see comment]. N Engl J Med. 2000;342(22):1622-1626. [pmid: 10833207].
Hirshkowitz M, Moore CA, O'Connor S, et al. Androgen and sleep-related erections. J Psychosom Res. 1997;42(6):541-546. [pmid: 9226601].
Hirst JF, Watson JP. Referrals aged 60+ to an inner-city psychosexual dysfunction clinic. Sexual & Marital Therapy. 1996;11(2):131-146.
Hofner K, Claes H, De Reijke TM, et al. Tamsulosin 0.4 mg once daily: effect on sexual function in patients with lower urinary tract symptoms suggestive of benign prostatic obstruction. Eur Urol. 1999;36(4):335-341. [pmid: 10473995].
Holt S. Natural approaches to promote sexual function: Part 1: Viagra versus a natural approach. Alternative & Complementary Therapies. 1999;5(4):204-208.
Holtkamp M, Weissinger F, Meierkord H. Erectile dysfunction with topiramate. Epilepsia. 2005;46(1):166-167. [pmid: 15660786].
Hong B, Ji YH, Hong JH, et al. A double-blind crossover study evaluating the efficacy of korean red ginseng in patients with erectile dysfunction: a preliminary report.[see comment]. Br J Urol. 2002;168(5):2070-2073.
Hopps CV, Mulhall JP. Novel agents for sexual dysfunction. BJU Int. 2003;92(6):534-538. [pmid: 14511028].
Horita H, Sato Y, Adachi H, et al. Effects of levodopa on nocturnal penile tumescence: a preliminary study. J Androl. 1998;19(5):619-624. [pmid: 9796623].
Howes OD, Wheeler MJ, Pilowsky LS, et al. Sexual function and gonadal hormones in patients taking antipsychotic treatment for schizophrenia or schizoaffective disorder. Hillside J Clin Psychiatry. 2007;68(3):361-367.
Howes Oliver D, Smith Shubulade, Aitchison Kathy JE. Comments on "Prolactin Levels and Erectile Function in Patients Treated With Risperidone." [References]. J Clin Psychopharmacol. 2005;25(4):393-394. [pmid: 16012288].
Huang ST, Hsieh ML. Different hemodynamic responses by color Doppler ultrasonography studies between sildenafil non-responders and responders. Asian J Androl. 2007;9(1):129-133. [pmid: 17187164].
Huang WJ, Chen KK, Chang LS. Correlation between voiding and erectile function in patients with symptomatic benign prostatic hyperplasia. Journal of the Chinese Medical Association: JCMA. 2005;68(4):178-182. [pmid: 15850068].
Hultling C. Partners' perceptions of the efficacy of sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Clin Pract 1999;Supplement.102–108.
Hummel S, Paisley S, Morgan A, et al. Clinical and cost-effectiveness of new and emerging technologies for early localised prostate cancer: A systematic review. Health Technol Assess. 2003;7(33):157p.
Hunter R H, Joy C B, Kennedy E et al. Risperidone versus typical antipsychotic medication for schizophrenia.[update of Cochrane Database Syst Rev. 2000;(2):CD000440; PMID: 10796543]. [Review][105 refs]. Cochrane Database Syst Rev 2003;(2):CD000440
Hyer SL, Duckworth K, Jones C. Managing erectile disorders in diabetes: The one stop andrology clinic. Practical Diabetes International. 1998;15(8):225-226.
Israilov S, Baniel J, Shmueli J, et al. Treatment program for erectile dysfunction in patients with cardiovascular diseases. Am J Cardiol. 2004;93(6):689-693. [pmid: 15019870].
Jackson G. Erectile dysfunction and cardiovascular disease.[see comment]. [Review] [46 refs]. Int J Clin Pract. 1999;53(5):363-368. [pmid: 10695101].
Jackson G. Treatment of erectile dysfunction in patients with cardiovascular disease: Guide to drug selection. Drugs. 2004;64(14):1533-1545. [pmid: 15233591].
Jackson G. Vardenafil - PDE5 inhibitor number 3. Int J Clin Pract. 2004;58(3):229. [pmid: 15117087].
Jackson G. PDE5 inhibitors: Looking beyond ED. Int J Clin Pract. 2003;57(3):159-160. [pmid: 12723713].
Jackson G. Sildenafil (Viagra): New data, new confidence in treating erectile dysfunction in the cardiovascular patient. Int J Clin Pract. 2002;56(2):75. [pmid: 11926708].
Jackson G. Phosphodiesterase 5 inhibition: Effects on the coronary vasculature. Int J Clin Pract. 2001;55(3):183-188. [pmid: 11351772].
Jackson G. The metabolic syndrome and erectile dysfunction: multiple vascular risk factors and hypogonadism. Eur Urol. 2006;50(3):426-427. [pmid: 16644094].
Jackson G, Sweeney M, Osterloh IH. Sildenafil citrate (Viagra(TM)): A cardiovascular overview. British Journal of Cardiology. 1999;6(6):325-334.
James J S. Frequent urination, leg cramps, leg weakness, erection difficulties: HIV myelopathy amino acid study. AIDS Treat News 2000;(344):3–4.
Jani AB. The effectiveness of combining hormone therapy and radiotherapy in the treatment of prostate cancer. Expert Opin Pharmacother. 2004;5(12):2469-2477. [pmid: 15571465].
Jani AB, Kao J, Heimann R, et al. Hormone therapy and radiotherapy for early prostate cancer: A utility-adjusted number needed to treat (NNT) analysis. Int J Radiat Oncol Biol Phys. 2005;61(3):687-694. [pmid: 15708246].
Jarow JP, Nana-Sinkam P, Sabbagh M, et al. Outcome analysis of goal directed therapy for impotence. Br J Urol. 1996;155(5):1609-1612.
Jeong SJ, Park K, Moon JD, et al. Bicycle saddle shape affects penile blood flow. Int J Impot Res. 2002;14(6):513-517. [pmid: 12494288].
Jordan GH. What's new in urology. J Am Coll Surg. 2003;197(3):444-457. [pmid: 12946801].
Kadioglu A, Erdogru T, Tellaloglu S. Evaluation of penile arteries in papaverine-induced erection with color Doppler ultrasonography. Arch Esp Urol. 1995;48(6):654-658. [pmid: 7661649].
Kamel HK, Morley JE. The management of erectile dysfunction. Reproductive Medicine Review. 2001;9(1):35-47.
Kang BJ, Lee SJ, Kim MD, et al. A placebo-controlled, double-blind trial of Ginkgo biloba for antidepressant-induced sexual dysfunction. Hum Psychopharmacol. 2002;17(6):279-284. [pmid: 12404672].
Kaplan SA, Meehan AG, Shah A. The age related decrease in testosterone is significantly exacerbated in obese men with the metabolic syndrome. What are the implications for the relatively high incidence of erectile dysfunction observed in these men?. Br J Urol. 2006;176(4 Pt 1):1524-1527.
Karlawish JH, Casarett D. Sildenafil for diabetic men with erectile dysfunction.[comment]. JAMA. 1999;282(10):940-941. [pmid: 10485673].
Kaufman JM, Hatzichristou DG, Mulhall JP, et al. Impotence and chronic renal failure: a study of the hemodynamic pathophysiology. Br J Urol. 1994;151(3):612-618.
Keijzers GB. Aviptadil (Senatek). [Review] [36 refs]. Curr Opin Investig Drugs. 2001;2(4):545-549.
Keles I, Aydin G, Orkun S, et al. Two clinical problems in elderly men: osteoporosis and erectile dysfunction. Arch Androl. 2005;51(3):177-184. [pmid: 16025856].
Kell P. Cardiovascular safety of sildenafil. Int J STD AIDS. 2002;13(7):439-443. [pmid: 12171661].
Keoghane SR, Sullivan ME, Miller MAW. The aetiology, pathogenesis and management of priapism. BJU Int. 2002;90(2):149-154. [pmid: 12081756].
Kerfoot WW, Park HY, Schwartz LB, et al. Characterization of calcium channel blocker induced smooth muscle relaxation using a model of isolated corpus cavernosum. Br J Urol. 1993;150(1):249-252.
Kernohan AF, McIntyre M, Hughes DM, et al. An oral yohimbine/L-arginine combination (NMI 861) for the treatment of male erectile dysfunction: a pharmacokinetic, pharmacodynamic and interaction study with intravenous nitroglycerine in healthy male subjects. Br J Clin Pharmacol. 2005;59(1):85-93. [pmid: 15606445].
Khalaf IM, Levinson IP. Erectile dysfunction in the Africa/Middle East Region: Epidemiology and experience with sildenafil citrate (Viagra). Int J Impot Res. 2003;15(SUPPL. 1):S1-S2. [pmid: 12825101].
Khan LA. Sildenafil citrate (Viagra). JK Pract. 2001;8(1):52-53.
Kilic S, Ergin H, Baydinc YC. Venlafaxine extended release for the treatment of patients with premature ejaculation: a pilot, single-blind, placebo-controlled, fixed-dose crossover study on short-term administration of an antidepressant drug. Int J Androl. 2005;28(1):47-52. [pmid: 15679621].
Kilic S, Salih M, Anafarta K, et al. Adenosine: a new agent in the diagnosis of impotence. Int J Impot Res. 1994;6(4):191-198. [pmid: 7795719].
Kim NN. Phosphodiesterase type 5 inhibitors: A biochemical and clinical correlation survey. Int J Impot Res. 2003;15(SUPPL. 5):S13-S19. [pmid: 14551572].
Kim NN, Dhir V, Azadzoi KM, et al. Pilot study of the endothelin-A receptor selective antagonist BMS-193884 for the treatment of erectile dysfunction. J Androl. 2001;23(1):76-83. [pmid: 11780926].
Kim SC, Seo KK, Lee SK, et al. Comparison of the synergistic effects of tamsulosin versus phentolamine on penile erection: In vitro and in vivo studies. Urol Res. 1999;27(6):437-444. [pmid: 10651132].
Kim SC, Seo KK, Park BD, et al. Risk factors for an early increase in dose of vasoactive agents for intracavernous pharmacotherapy. Urol Int. 2000;65(4):204-207. [pmid: 11112870].
Kimoto Y, Sakamoto S, Fujikawa K, et al. Up-titration of vardena fi l dose from 10 mg to 20 mg improved erectile function in men with spinal cord injury. Int J Urol. 2006;13(11):1428-1433. [pmid: 17083398].
Kirby RS. Report from London. Prostate Cancer & Prostatic Diseases. 2005;8(4):299. [pmid: 16319940].
Kirby RS, Andersen M, Gratzke P, et al. A combined analysis of double-blind trials of the efficacy and tolerability of doxazosin-gastrointestinal therapeutic system, doxazosin standard and placebo in patients with benign prostatic hyperplasia. BJU Int. 2001;87(3):192-200. [pmid: 11167641].
Kirby RS, O'Leary MP, Carson C. Efficacy of extended-release doxazosin and doxazosin standard in patients with concomitant benign prostatic hyperplasia and sexual dysfunction. BJU Int. 2005;95(1):103-109. [pmid: 15638905].
Kiriakova N, Kiriakov A, Schneider E, et al. Therapeutic effect of essential phospholipids on functional sexual disorders in males. Journal of the European Academy of Dermatology & Venereology. 1998;11(2):191-193. [pmid: 9784056].
Kleinberg DL, Davis JM, De Coster R, et al. Prolactin levels and adverse events in patients treated with risperidone.[see comment]. J Clin Psychopharmacol. 1999;19(1):57-61. [pmid: 9934944].
Kley HK, Stremmel W, Kley JB, et al. Testosterone treatment of men with idiopathic hemochromatosis. Clin Investig. 1992;70(7):566-572.
Kloner RA, Brindis RG, Cheitlin MD, et al. Roundtable discussion: Tadalafil study group. Am J Cardiol. 2003;92(9 SUPPL. 1):58M-65M.
Kloner RA, Hutter AM, Emmick JT, et al. Time course of the interaction between tadalafil and nitrates.[see comment]. J Am Coll Cardiol. 2003;42(10):1855-1860. [pmid: 14642699].
Kloner RA, Jackson G, Emmick JT, et al. Interaction between the phosphodiesterase 5 inhibitor, tadalafil and 2 alpha-blockers, doxazosin and tamsulosin in healthy normotensive men. Br J Urol. 2004;172(5:Pt 1):t-40.
Klotz T, Mathers MJ, Braun M, et al. Effectiveness of oral L-arginine in first-line treatment of erectile dysfunction in a controlled crossover study. Urol Int. 1999;63(4):220-223. [pmid: 10743698].
Knegtering R, Castelein S, Bous H, et al. A Randomized Open-Label Study of the Impact of Quetiapine Versus Risperidone on Sexual Functioning. J Clin Psychopharmacol. 2004;24(1):56-61. [pmid: 14709948].
Knoll LD, Benson RC, Bilhartz DL, et al. A randomized crossover study using yohimbine and isoxsuprine versus pentoxifylline in the management of vasculogenic impotence. Br J Urol. 1996;155(1):144-146.
Kobayashi T, Okuno H, Nishiyama H, et al. Adult-onset idiopathic hypogonadotropic hypogonadism presented with erectile and ejaculatory disorder. Int J Urol. 2002;9(10):604-606. [pmid: 12445243].
Kramer-Levien D J. Papaverine—the medical implant. AUAA J 1987;7(4):13-Jun.
Krause W, Mueller U, Mazur A. Measurement of steroid levels in saliva in a population-based survey of lifestyle, medical conditions, marriage, sex life and hormone status in aging men: A feasibility study. Aging Male. 2002;5(4):203-215. [pmid: 12630067].
Kuba R, Pohanka M, Zakopcan J, et al. Sexual dysfunctions and blood hormonal profile in men with focal epilepsy. Epilepsia. 2006;47(12):2135-2140. [pmid: 17201714].
Kukreja RC, Ockaili R, Salloum F, et al. Cardioprotection with phosphodiesterase-5 inhibition - A novel preconditioning strategy. Journal of Molecular & Cellular Cardiology. 2004;36(2):165-173. [pmid: 14871543].
Kunelius P, Hakkinen J, Lukkarinen O. Is high-dose yohimbine hydrochloride effective in the treatment of mixed-type impotence? A prospective, randomized, controlled double-blind crossover study. Urology. 1997;49(3):441-444. [pmid: 9123711].
Kupecz D. Alprostadil for the treatment of erectile dysfunction. J Am Acad Nurse Pract. 1996;21(5):143-145.
Kupelian V, Shabsigh R, Travison TG, et al. Is there a relationship between sex hormones and erectile dysfunction? Results from the Massachusetts Male Aging Study. Br J Urol. 2006;176(6 Pt 1):2584-2588.
Kvistborg A, Halse J, Bakke S, et al. Long-term treatment of macroprolactinomas with CV 205–502. Acta Endocrinol (Copenh). 1993;128(4):301-307. [pmid: 8098891].
La Pera G, Franco Giannotti C, Taggi F, et al. Prevalence of sexual disorders in those young males who later become drug abusers. J Sex Marital Ther. 2003;29(2):149-156. [pmid: 12623766].
La Vignera S, Calogero AE, Cannizzaro MA, et al. Erectile vascular dysfunction and analysis of the risk factors related to it. Clinical experience. Minerva Endocrinol. 2007;32(1):17-21. [pmid: 17353863].
Labbate Lawrence A. "Sex and serotonin reuptake inhibitor antidepressants": Erratum. Psychiatr Ann. 1999;29(12):683.
Labbate Lawrence A, Croft Harry A, Oleshansky Marvin AE. Antidepressant-Related Erectile Dysfunction: Management via Avoidance, Switching Antidepressants, Antidotes, and Adaptation. [References]. Hillside J Clin Psychiatry. 2003;64(Suppl 10):11-19.
Labbate Lawrence A, Grimes Jamie, Hines Alan, et al. Sexual dysfunction induced by serotonin reuptake antidepressants. J Sex Marital Ther. 1998;24(1):3-12. [pmid: 9509375].
Lamberg L. New drug for erectile dysfunction boon for many, ‘viagravation’ for some. J Am Med Assoc. 1998;280(10):867-869.
Larson TR. Current treatment options for benign prostatic hyperplasia and their impact on sexual function. Urology. 2003;61(4):692-698. [pmid: 12670545].
Lasaponara F, Paradiso M, Milan MG, et al. Erectile dysfunction after kidney transplantation: our 22 years of experience.[see comment]. Transplant Proc. 2004;36(3):502-504. [pmid: 15110572].
Latini DM, Penson DF, Lubeck DP, et al. Longitudinal differences in disease specific quality of life in men with erectile dysfunction: Results from the exploratory comprehensive evaluation of erectile dysfunction study. Br J Urol. 2003;169(4):1437-1442.
Laumann Edward O, West Suzanne, Glasser Dale, et al. Prevalence and Correlates of Erectile Dysfunction by Race and Ethnicity Among Men Aged 40 or Older in the United States: From the Male Attitudes Regarding Sexual Health Survey. [References]. Br J Sex Med. 2007;4(1):57-65.
Lawless C, Cree J. Oral medications in the management of erectile dysfunction. [Review] [15 refs]. J Am Board Fam Pract. 1998;11(4):307-314. [pmid: 9719353].
Lawrence IG, Price DE, Howlett TA, et al. Correcting impotence in the male dialysis patient: experience with testosterone replacement and vacuum tumescence therapy. Am J Kidney Dis. 1998;31(2):313-319. [pmid: 9469503].
Lebret T, Herve JM, Gorny P, et al. Efficacy and safety of a novel combination of L-arginine glutamate and yohimbine hydrochloride: a new oral therapy for erectile dysfunction. Eur Urol. 2002;41(6):608-613. [pmid: 12074777].
Lee W R. The role of androgen deprivation therapy combined with prostate brachytherapy. [Review][31 refs]. Urology 2002;60(3:Suppl 1):Suppl-44.
Lehmann K, Casella R, Blochlinger A, et al. Reasons for discontinuing intracavernous injection therapy with prostaglandin E1 (alprostadil). Urology. 1999;53(2):397-400. [pmid: 9933062].
Lehmann K, John H, Kacl G, et al. Variable response to intracavernous prostaglandin E1 testing for erectile dysfunction. Urology. 1999;54(3):539-543. [pmid: 10475368].
Lenze EJ, Karp JF, Mulsant BH, et al. Somatic symptoms in late-life anxiety: Treatment issues. Journal of Geriatric Psychiatry & Neurology. 2005;18(2):89-96. [pmid: 15911937].
Lenzi A. The role of the medical andrologist in the assisted reproduction era. J Endocrinol Invest. 2003;26(3):268-273. [pmid: 12809180].
Leslie SJ, Atkins G, Oliver JJ, et al. No adverse hemodynamic interaction between sildenafil and red wine. Clinical Pharmacology & Therapeutics. 2004;76(4):365-370. [pmid: 15470336].
Levien T, Baker DE. Lepirudin and sildenafil citrate. Hosp Pharm. 1998;33(12):1524-1552.
Levine SB. A slightly different idea. Arch Sex Behav. 2005;34(1):38-39. [pmid: 16092025].
Levy MM. Benefits being missed [5]. Can Pharm J. 2005;274(7334):109.
Lexchin J. New drugs with novel therapeutic characteristics. Have they been subject to randomized controlled trials?. Can Fam Physician. 2002;48(SEPT.):1487-1492. [pmid: 12371307].
Li JY, Li XY, Li M, et al. Decline of serum levels of free testosterone in aging healthy Chinese men. Aging Male. 2005;8(34):203-206. [pmid: 16390747].
Licht MR. Use of oral sildenafil (Viagra) in the treatment of erectile dysfunction. [Review] [13 refs]. Compr Ther. 1999;25(2):90-94. [pmid: 10091013].
Lim P H C, Moorthy P, Benton K G F. The clinical safety of Viagra. Ann N Y Acad Sci 2002;962(pp 378–388):-388.
Limoge JP, Olins E, Henderson D, et al. Minimally invasive therapies in the treatment of erectile dysfunction in anticoagulated cases: a study of satisfaction and safety. Br J Urol. 1996;155(4):1276-1279.
Lin CS, Xin ZC, Lin G, et al. Phosphodiesterases as therapeutic targets. Urology. 2003;61(4):685-691. [pmid: 12670544].
Lincoln TM. Cyclic GMP and phosphodiesterase 5 inhibitor therapies: What's on the horizon. Mol Pharmacol. 2004;66(1):11-13. [pmid: 15213291].
Lindsey I. What is the incidence of sexual dysfunction in males following rectal excision for benign and malignant diseases?. National Research Register 2000;2000.
Linet OI, Neff LL. Intracavernous prostaglandin E1 in erectile dysfunction. Clin Investig. 1994;72(2):139-149.
Linnebur SA. Pharmacotherapy update: What's new about old medications. Annals of Long Term Care. 2004;12(9):34-44.
Lipshultz LI. Injection therapy for erectile dysfunction. N Engl J Med. 1996;334(14):913-914. [pmid: 8596577].
Lipshultz LI, Kim ED. Treatment of erectile dysfunction in men with diabetes. J Am Med Assoc. 1999;281(5):465-466.
Llisterri JL, Lozano Vidal JV, Aznar Vicente J, et al. Sexual dysfunction in hypertensive patients treated with losartan. Am J Med Sci. 2001;321(5):336-341. [pmid: 11370797].
Long RL, Sherman LS, Lombardi TJ. A goal-oriented, cost-effective approach to the diagnosis and treatment of 24 male erectile dysfunction. [Review] [24 refs]. J Ky Med Assoc. 1995;93(11):500-508. [pmid: 8778212].
Loudon Julia B. Potential confusion between erectile dysfunction and premature ejaculation: An evaluation of men presenting with erectile difficulty at a sex therapy clinic. Sexual & Marital Therapy. 1998;13(4):397-403.
Lu J, SJ Fan J, Zhu J, et al. The prospective and randomized control study of Viagra combined with Andriol in the treatment of ED in the aging male. Chinese Journal of Andrology. 2003;17(3):194-196.
Lue TF. Erectile dysfunction. N Engl J Med. 2000;342(24):1802-1813. [pmid: 10853004].
Lue TF. Impotence after radical pelvic surgery: physiology and management. [Review] [56 refs]. Urol Int. 1991;46(3):259-265. [pmid: 1926639].
Lukkarinen O, Tonttila P, Hellstrom P, et al. Non-prosthetic surgery in the treatment of erectile dysfunction. A retrospective study of 45 impotent patients in the University of Oulu. Scandinavian Journal of Urology & Nephrology. 1998;32(1):42-46. [pmid: 9561573].
Lunenfeld B, Saad F, Hoesl CE. ISA, ISSAM and EAU recommendations for the investigation, treatment and monitoring of late-onset hypogonadism in males: Scientific background and rationale. Aging Male. 2005;8(2):59-74. [pmid: 16096160].
Maan Z, Arya M, Shergill I, et al. Peyronie's disease: An update of the medical management. Expert Opin Pharmacother. 2004;5(4):799-805. [pmid: 15102564].
Maas R, Schwedhelm E, Albsmeier J, et al. The pathophysiology of erectile dysfunction related to endothelial dysfunction and mediators of vascular function. Vasc Med. 2002;7(3):213-225. [pmid: 12553745].
Mahmud A, Hennessy M, Feely J. Effect of sildenafil on blood pressure and arterial wave reflection in treated hypertensive men. J Hum Hypertens. 2001;15(10):707-713. [pmid: 11607801].
Maier U, Koinig G. Andrological findings in young patients under long-term antidepressive therapy with clomipramine. Psychopharmacology (Berl). 1994;116(3):357-359. [pmid: 7892427].
Mak R, De Backer G, Kornitzer M, et al. Prevalence and correlates of erectile dysfunction in a population-based study in Belgium. Eur Urol. 2002;41(2):132-138. [pmid: 12074399].
Manasia P, Pomerol J, Ribe N, et al. Comparison of the efficacy and safety of 90 mg versus 20 mg fluoxetine in the treatment of premature ejaculation. Br J Urol. 2003;170(1):164-165.
Manganiello V. International Journal of Impotence Research: Editorial commentary. Int J Impot Res. 2004;16(SUPPL. 1):S1-S3. [pmid: 15224126].
Mann K, Klingler T, Noe S, et al. Effects of yohimbine on sexual experiences and nocturnal penile tumescence and rigidity in erectile dysfunction. Arch Sex Behav. 1996;25(1):1-16. [pmid: 8714425].
Mann RD. Introduction - Tadalafil. Journal of Drug Evaluation. 2004;2(8):223.
Mann RD. Executive summary sildenafil citrate (Viagra). Journal of Drug Evaluation. 2003;1(7):221-223.
Manning M, Junemann KP, Scheepe JR, et al. Long-term followup and selection criteria for penile revascularization in erectile failure.[see comment]. Br J Urol. 1998;160(5):1680-1684.
Marberger M, Roehrborn CG, Marks LS, et al. Relationship among serum testosterone, sexual function, and response to treatment in men receiving dutasteride for benign prostatic hyperplasia. Journal of Clinical Endocrinology & Metabolism. 2006;91(4):1323-1328. [pmid: 16434455].
Margel D, Tal R, Livne PM, et al. Predictors of erectile function improvement in obstructive sleep apnea patients with long-term CPAP treatment. Int J Impot Res. 2005;17(2):186-190. [pmid: 15510189].
Marquer C, Bressolle F. Moxisylyte: A review of its pharmacodynamic and pharmacokinetic properties, and its therapeutic use in impotence. Fundam Clin Pharmacol. 1998;12(4):377-387. [pmid: 9711459].
Martin DJ, Badwan K, Parker M, et al. Transdermal application of verapamil gel to the penile shaft fails to infiltrate the tunica albuginea. Br J Urol. 2002;168(6):2483-2485.
Martins FE, Reis JP. Visual erotic stimulation test for initial screening of psychogenic erectile dysfunction: a reliable noninvasive alternative?. Br J Urol. 1997;157(1):134-139.
Masand PS, Ashton AK, Gupta S, et al. Sustained-release bupropion for selective serotonin reuptake inhibitor-induced sexual dysfunction: a randomized, double-blind, placebo-controlled, parallel-group study.[see comment]. Am J Psychiatry. 2001;158(5):805-807. [pmid: 11329407].
Maytom MC, Derry FA, Dinsmore WW, et al. A two-part pilot study of sildenafil (VIAGRA) in men with erectile dysfunction caused by spinal cord injury. Spinal Cord. 1999;37(2):110-116. [pmid: 10065749].
McCarthy Barry W. Relapse prevention strategies and techniques with erectile dysfunction. J Sex Marital Ther. 2001;27(1):1-8. [pmid: 11224950].
McClellan KJ, Goa KL. Transdermal testosterone. [Review] [17 refs]. Drugs. 1998;55(2):253-258. [pmid: 9506244].
McConnell JD, Roehrborn CG, Bautista OM, et al. The Long-Term Effect of Doxazosin, Finasteride, and Combination Therapy on the Clinical Progression of Benign Prostatic Hyperplasia. N Engl J Med. 2003;349(25):2387-2398. [pmid: 14681504].
McCullough AR, Barada JH, Fawzy A, et al. Achieving treatment optimization with sildenafil citrate (Viagra) in patients with erectile dysfunction. Urology. 2002;60(2 Suppl 2):28-38. [pmid: 12414331].
McKinlay J B. The worldwide prevalence and epidemiology of erectile dysfunction. [Review][17 refs]. Int J Impot Res 2000;12Suppl-S11.
McMahon C. Comparison of erectile responses to differing doses of prostaglandin PGE1 in an attempt to standardise pharmacological diagnosis of impotence. Journal of Assisted Reproduction & Genetics 1992;9265A
McMahon CG. Nonsurgical treatment of cavernosal venous leakage. Urology. 1997;49(1):97-100. [pmid: 9000193].
McMahon CG. Treatment of Erectile Dysfunction with Chronic Dosing of Tadalafil. Eur Urol. 2006;50(2):215-217. [pmid: 16844542].
McMahon CG, Stuckey BGA, Andersen M, et al. Efficacy of sildenafil citrate (viagra) in men with premature ejaculation. Br J Sex Med. 2005;2(3):368-375.
Mealy NE. NBI-69733. Drugs of the Future. 2004;29(6):642.
Mealy NE. GPI-1485. Drugs of the Future. 2004;29(6):640.
Mealy NE. EMR-62203. Drugs of the Future. 2004;29(6):639.
Mealy NE. Dasantafil. Drugs of the Future. 2004;29(6):633.
Mealy NE. DA-8159. Drugs of the Future. 2004;29(6):631.
Mealy NE. Avanafil. Drugs of the Future. 2004;29(6):628-629.
Mealy NE, Bayes M. PT-141. Drugs of the Future. 2004;29(11):1177.
Mealy NE, Bayes M. ABT-724. Drugs of the Future. 2005;30(9):935.
Mehdiyev T V. Intracavernous injection probe of vasoactive preparations in the diagnosis of erectile dysfunctions in patients with diabetes mellitus. Azerbaidzhanskii Meditsinskii Zhurnal 2002;(pp 17–19):-19.
Meinhardt W, Kropman RF, Vermeij P, et al. The influence of medication on erectile function. Int J Impot Res. 1997;9(1):17-26. [pmid: 9138055].
Melman A, Bar-Chama N, McCullough A, et al. The first human trial for gene transfer therapy for the treatment of erectile dysfunction: preliminary results. Eur Urol. 2005;48(2):314-318. [pmid: 15964135].
Mendelson WB, Gujavarty K, Slintak C, et al. Reported sexual dysfunction in obstructive sleep apnea patients. Ann Clin Psychiatry. 1990;2(2):93-101.
Merrick GS, Wallner KE, Butler WM. Minimizing prostate brachytherapy-related morbidity. Urology. 2003;62(5):786-792. [pmid: 14624895].
Meyhoff HH, Rosenkilde P, Bodker A. Non-invasive management of impotence with transcutaneous nitroglycerin. Br J Urol. 1992;69(1):88-90. [pmid: 1737261].
Migliari R, Muscas G, Usai E. Effect of Casodex on sleep-related erections in patients with advanced prostate cancer. Br J Urol. 1992;148(2 I):338-341.
Mikhail N. Efficacy and safety of sildenafil in patients with congestive heart failure [7]. Arch Intern Med. 2004;164(18):2067-2068. [pmid: 15477449].
Millard RJ, Stricker PD, Lynch WJ, et al. Risks of self-injection therapy for impotence. Med J Aust. 1996;165(2):117-118. [pmid: 8692055].
Miller DC, Wei JT, Dunn RL, et al. Use of medications or devices for erectile dysfunction among long-term prostate cancer treatment survivors: potential influence of sexual motivation and/or indifference. Urology. 2006;68(1):166-171. [pmid: 16844457].
Miller N, Smolkin ME, Bissonette E, et al. Undetectable prostate specific antigen at 6–12 months: a new marker for early success in hormonally treated patients after prostate brachytherapy. Cancer. 2005;103(12):2499-2506. [pmid: 15852361].
Mills RD, Sethia KK. Maximisation of the erectile response in the investigation of impotence. Int J Impot Res. 1999;11(1):29-32. [pmid: 10098951].
Milman HA, Arnold SB, Rivera-Miranda G, et al. Neurologic, psychological, and aggressive disturbances with sildenafil. Ann Pharmacother. 2002;36(78):1129-1134. [pmid: 12086542].
Mittleman MM, Rosen RC. Evaluating clinical trial design results and analysis of drug treatments for erectile dysfunction. Int J Impot Res. 2003;15(4):x-xiii.
Miwa Y, Kaneda T, Yokoyama O. Correlation between the Aging Males' Symptoms Scale and sex steroids, gonadotropins, dehydroepiandrosterone sulfate, and growth hormone levels in ambulatory men. Br J Sex Med. 2006;3(4):723-726.
Mohr BA, Bhasin S, Link CL, et al. The effect of changes in adiposity on testosterone levels in older men: longitudinal results from the Massachusetts Male Aging Study. Eur J Endocrinol. 2006;155(3):443-452. [pmid: 16914599].
Montejo A L, Llorca G, Izquierdo J A et al. Incidence of sexual dysfunction associated with antidepressant agents: a prospective multicenter study of 1022 outpatients. Spanish Working Group for the Study of Psychotropic-Related Sexual Dysfunction.[see comment]. Hillside J Clin Psychiatry 2001;62Suppl-21.
Montejo-Gonzalez AL, Llorca G, Izquierdo JA, et al. SSRI-induced sexual dysfunction: fluoxetine, paroxetine, sertraline, and fluvoxamine in a prospective, multicenter, and descriptive clinical study of 344 patients. Journal of Sex and Marital Therapy. 1997;23(3):176-194. [pmid: 9292833].
Montorsi F. A multicenter, randomized, double-blind, crossover study to evaluate patient preference between tadalafil and sildenafil: Editorial comment. Eur Urol. 2004;45(4):508-509.
Montorsi F, Burnett AL. Erectile dysfunction after radical prostatectomy. BJU Int. 2004;93(1):1-2. [pmid: 14678354].
Montorsi F, Briganti A, Salonia A, et al. Current and Future Strategies for Preventing and Managing Erectile Dysfunction Following Radical Prostatectomy. Eur Urol. 2004;45(2):123-133. [pmid: 14733995].
Montorsi F, Guazzoni G, Bocciardi A, et al. Improved minimally-invasive assessment of penile haemodynamics: the combination of colour Doppler sonography and injection-stimulation test. Int J Impot Res. 1995;7(1):33-40. [pmid: 7670591].
Montorsi F, Perani D, Anchisi D, et al. Brain activation patterns during video sexual stimulation following the administration of apomorphine: results of a placebo-controlled study. Eur Urol. 2003;43(4):405-411. [pmid: 12667722].
Montorsi F, Strambi LF, Guazzoni G, et al. Effect of yohimbine-trazodone on psychogenic impotence: a randomized, double-blind, placebo-controlled study. Urology. 1994;44(5):732-736. [pmid: 7974947].
Morales A. Men's aging and sexual disorders: An update on diagnosis and treatment. Rev Endocr Metab Disord. 2005;6(2):85-92. [pmid: 15843879].
Morales Alvaro, Condra Michael, Heaton Jeremy P, et al. Impotence: Organic factors and management approach. Sexual & Marital Therapy. 1991;6(2):97-106.
Moreira ED, Lbo CF, Diament A, et al. Incidence of erectile dysfunction in men 40 to 69 years old: results from a population-based cohort study in Brazil. Urology. 2003;61(2):431-436. [pmid: 12597962].
Moreira E D, Lisboa Lobo C F, Villa M et al. Prevalence and correlates of erectile dysfunction in Salvador, northeastern Brazil: a population-based study. Int J Impot Res 2002;14Suppl-9.
Morley John E, Kaiser Fran E. Aging and sexuality. Vellas, Bruno (Ed); Albarede, J 1992;-L(Ed):1992–165.
Mulhall JP, bdel-Moneim A, Abobakr R, et al. Improving the accuracy of vascular testing in impotent men: correcting hemodynamic alterations using a vasoactive medication re-dosing schedule. Br J Urol. 2001;166(3):923-926.
Mulhall JP, Daller M, Traish AM, et al. Intracavernosal forskolin: Role in management of vasculogenic impotence resistant to standard 3-agent pharmacotherapy. Br J Urol. 1997;158(5):1752-1759.
Mulhall JP, Valenzuela R, Aviv N, et al. Effect of testosterone supplementation on sexual function in hypogonadal men with erectile dysfunction. Urology. 2004;63(2):348-352. [pmid: 14972487].
Mulligan T, Schmitt B. Testosterone for erectile failure. J Gen Intern Med. 1993;8(9):517-521. [pmid: 8410427].
Mulligan T, Frick MF, Zuraw QC, et al. Prevalence of hypogonadism in males aged at least 45 years: the HIM study. Int J Clin Pract. 2006;60(7):762-769. [pmid: 16846397].
Muneer A, Ralph DJ, Minhas S. Sildenafil citrate (Viagra). Journal of Drug Evaluation. 2003;1(7):225-246.
Munoz M, Bancroft J, Beard M. Evaluating the effects of an alpha-2 adrenoceptor antagonist on erectile function in the human male. 2. The erectile response to erotic stimuli in men with erectile dysfunction, in relation to age and in comparison with normal volunteers. Psychopharmacology (Berl). 1994;115(4):471-477. [pmid: 7871091].
Munoz M, Bancroft J, Turner M. Evaluating the effects of an alpha-2 adrenoceptor antagonist on erectile function in the human male. 1. The erectile response to erotic stimuli in volunteers. Psychopharmacology (Berl). 1994;115(4):463-470. [pmid: 7871090].
Murphy AM, O'Leary M. Failure of the Ambicor inflatable penile prosthesis to deflate. Int J Impot Res. 2005;17(3):291-292. [pmid: 15605073].
Murphy JC, Srinivas S, Terris MK. Flutamide administration at 500 mg daily has similar effects on serum testosterone to 750 mg daily. J Androl. 2004;25(4):630-634. [pmid: 15223852].
Nakata M, Takashima S, Kaminou T, et al. Embolotherapy for venous impotence: use of ethanol. Journal of Vascular & Interventional Radiology. 2000;11(8):1053-1057. [pmid: 10997470].
Nakonezny PA, Byerly MJ, Rush AJ. The relationship between serum prolactin level and sexual functioning among male outpatients with schizophrenia or schizoaffective disorder: A randomized double-blind trial of risperidone vs. quetiapine. J Sex Marital Ther. 2007;33(3):203-216. [pmid: 17454518].
Nandwani R, Gourlay Y. Possible interaction between sildenafil and HIV combination therapy [1]. Lancet. 1999;353(9155):840. [pmid: 10459981].
Narayan P, Trachtenberg J, Lepor H, et al. A dose-response study of the effect of flutamide on benign prostatic hyperplasia: results of a multicenter study. Urology. 1996;47(4):497-504. [pmid: 8638357].
Neese Leah E, Schover Leslie R, Klein Eric A, et al. Finding help for sexual problems after prostate cancer treatment: A phone survey of men's and women's perspectives. [References]. Psychooncology. 2003;12(5):463-473. [pmid: 12833559].
Neumeyer K, Kirkpatrick P. Tadalafil and vardenafil. Nat Rev Genet. 2004;3(4):295-296.
Nicolosi A, Moreira ED, Shirai M, et al. Epidemiology of erectile dysfunction in four countries: cross-national study of the prevalence and correlates of erectile dysfunction. Urology. 2003;61(1):201-206. [pmid: 12559296].
Nieschlag E, Swerdloff R, Behre HM, et al. Investigation, treatment and monitoring of late-onset hypogonadism in males: ISA, ISSAM, and EAU recommendations. Int J Androl. 2005;28(3):125-127. [pmid: 15910536].
Nurnberg HG, Seidman SN, Gelenberg AJ, et al. Depression, antidepressant therapies, and erectile dysfunction: clinical trials of sildenafil citrate (Viagra) in treated and untreated patients with depression. Urology. 2002;60(2 Suppl 2):58-66. [pmid: 12414334].
Nurnberg H, George. Erectile Dysfunction and Comorbid Depression: Prevalence, Treatment Strategies, and Associated Medical Conditions. [References]. Hillside J Clin Psychiatry. 2003;64(Suppl10):3-4.
O'Sullivan JD. Apomorphine as an alternative to sildenafil in Parkinson's disease. [References]. Journal of Neurology, Neurosurgery & Psychiatry. 2002;72(5):681.
Oefelein MG. Time to normalization of serum testosterone after 3-month luteinizing hormone-releasing hormone agonist administered in the neoadjuvant setting: implications for dosing schedule and neoadjuvant study consideration.[see comment]. Br J Urol. 1998;160(5):1685-1688.
Ojumu A, Dobs AS. Is Hypogonadism a Risk Factor for Sexual Dysfunction?. J Androl. 2003;24(6 SUPPL.):S46-S51. [pmid: 14581495].
Onu PE. Depot medroxyprogesterone in the management of benign prostatic hyperplasia. Eur Urol. 1995;28(3):229-235. [pmid: 8536777].
Opsomer RJ, Wese FX, De Groote P, et al. The external vacuum device in the management of erectile dysfunction. Acta Urol Belg. 1997;65(4):13-16. [pmid: 9497591].
Osterloh IH, Riley A. Clinical update on sildenafil citrate. [Review] [58 refs]. Br J Clin Pharmacol. 2002;53(3):219-223. [pmid: 11874383].
Owens J. Seeking selectivity. Nat Rev Genet. 2005;4(2):106.
Ozbek E, Yurekli M, Soylu A, et al. The role of adrenomedullin in varicocele and impotence. BJU Int. 2000;86(6):694-698. [pmid: 11069379].
Ozdel O, Oguzhanoglu A, Oguzhanoglu NK, et al. A follow-up study of male sexual disorders: The neurophysiological assessments, anxiety-depression levels, and response to fluoxetine treatment [10]. J Clin Psychopharmacol. 2004;24(4):461-463. [pmid: 15232347].
Paice Judith A, Penn Richard D, Ryan Will G. Altered sexual function and decreased testosterone in patients receiving intraspinal opioids. J Pain Symptom Manage. 1994;9(2):126-131. [pmid: 7517429].
Paick JS, Yang JH, Kim SW, et al. Severity of erectile dysfunction in married impotent patients: interrelationship with anthropometry, hormones, metabolic profiles and lifestyle. Int J Urol. 2007;14(1):48-53. [pmid: 17199860].
Paick JS, Yang JH, Kim SW, et al. The role of prolactin levels in the sexual activity of married men with erectile dysfunction. BJU Int. 2006;98(6):1269-1273. [pmid: 17125484].
Paick SH, Meehan A, Lee M, et al. The relationship among lower urinary tract symptoms, prostate specific antigen and erectile dysfunction in men with benign prostatic hyperplasia: results from the proscar long-term efficacy and safety study. Br J Urol. 2005;173(3):903-907.
Palha AP, Gomes FA, Martins AS, et al. [Clinical, multicentric, and open study to evaluate the efficacy of and tolerance to sildenafil in patients with erectile dysfunction]. Acta Med Port. 2002;15(4):249-256. [pmid: 12525018].
Pan CC, Lin JSN, Wong WS. Comparison of effect on erection between vacuum constriction devices and intra-cavernous injection of prostaglandin E1. Asian J Surg. 1997;20(2):162-166.
Papatsoris AG, Deliveliotis C, Singer C, et al. Erectile dysfunction in Parkinson's disease. Urology. 2006;67(3):447-451. [pmid: 16504269].
Parazzini F, Menchini Fabris F, Bortolotti A, et al. Frequency and determinants of erectile dysfunction in Italy. Eur Urol. 2000;37(1):43-49. [pmid: 10671784].
Paris G, Sponsel WE, Sandoval SS, et al. Sildenafil increases ocular perfusion. Int Ophthalmol. 2001;23(46):355-358. [pmid: 11944862].
Parker C. The Scandinavian Prostate Cancer Group Study: The case for conservative management. BJU Int. 2005;96(7):952-953. [pmid: 16225505].
Parsons JK, Marschke P, Maples P, et al. Effect of methylprednisolone on return of sexual function after nerve-sparing radical retropubic prostatectomy. Urology. 2004;64(5):987-990. [pmid: 15533491].
Patankar M. Sildenafil citrate. J Indian Med Assoc 2000;98(12):
Patterson D, Kloner R, Effron M, et al. The effect of tadalafil on the time to exercise-induced myocardial ischaemia in subjects with coronary artery disease. Br J Clin Pharmacol. 2005;60(5):459-468. [pmid: 16236035].
Pegge NC, Twomey AM, Vaughton K, et al. The role of endothelial dysfunction in the pathophysiology of erectile dysfunction in diabetes and in determining response to treatment. Diabet Med. 2006;23(8):873-878. [pmid: 16911625].
Penson DF, Feng Z, Kuniyuki A, et al. General quality of life 2 years following treatment for prostate cancer: what influences outcomes? Results from the prostate cancer outcomes study.[see comment]. Am J Clin Oncol. 2003;21(6):1147-1154.
Perez Martin A, Skinner Eila C, Meyerowitz Beth EE. Sexuality and intimacy following radical prostatectomy: Patient and partner perspectives. [References]. Health Psychol. 2002;21(3):288-293. [pmid: 12027035].
Perimenis P, Athanasopoulos A, Papathanasopoulos P, et al. Gabapentin in the management of the recurrent, refractory, idiopathic priapism. Int J Impot Res. 2004;16(1):84-85. [pmid: 14963477].
Pescatori ES, Calpista A, Artibani W, et al. Self-injection devices for intracavernosal pharmacotherapy: operational classification and safety considerations. Int J Impot Res. 1996;8(2):53-57. [pmid: 8858390].
Pescatori ES, Silingardi V, Galeazzi GM, et al. Audiovisual sexual stimulation by virtual glasses is effective in inducing complete cavernosal smooth muscle relaxation: a pharmacocavernosometric study. Int J Impot Res. 2000;12(2):83-88. [pmid: 11052633].
Phelps JS, Jain A, Monga M. The PsychoedPlusMed approach to erectile dysfunction treatment: the impact of combining a psychoeducational intervention with sildenafil. J Sex Marital Ther. 2004;30(5):305-314. [pmid: 15672598].
Philipp M, Kohnen R, Benkert O. A comparison study of moclobemide and doxepin in major depression with special reference to effects on sexual dysfunction. Int Clin Psychopharmacol. 1993;7(34):149-153. [pmid: 8468436].
Philipp M, Tiller JWG, Baier D, et al. Comparison of moclobemide with selective serotonin reuptake inhibitors (SSRIs) on sexual function in depressed adults. Eur Neuropsychopharmacol. 2000;10(5):305-314. [pmid: 10974600].
Phillips BG, Kato M, Pesek CA, et al. Sympathetic activation by sildenafil.[see comment]. Circulation. 2000;102(25):3068-3073. [pmid: 11120696].
Pirotte B, de Tullio P, Antoine MH, et al. New insights into the development of ATP-sensitive potassium channel openers. Expert Opinion on Therapeutic Patents. 2005;15(5):497-504.
Pisters LL, von Eschenbach AC, Scott SM, et al. The efficacy and complications of salvage cryotherapy of the prostate. J Urol. 1997;157(3):921-925. [pmid: 9072600].
Pittler M, Ernst E. Trials have shown yohimbine is effective for erectile dysfunction [14]. Br Med J. 1998;317(7156):478. [pmid: 9703549].
Polak K, Wimpissinger B, Berisha F, et al. Effects of sildenafil on retinal blood flow and flicker-induced retinal vasodilatation in healthy subjects. Invest Ophthalmol Vis Sci. 2003;44(11):4872-4876. [pmid: 14578411].
Pollack Mark H, Reiter Stewart, Hammerness Paul. Genitourinary and sexual adverse effects of psychotropic medication. Int J Psychiatry Med. 1992;22(4):305-327. [pmid: 1363418].
Pomerantz JM. Viagra and medical necessity. Drug Benefit Trends. 2002;14(10):33-40.
Pommerville P J. From bedside to bed. Recovery of sexual function after prostate cancer. Can Fam Physician 2005;51(JULY):941–943+948.
Porst HC. Re-dosing of prostaglandin-E1 versus prostaglandin-E1 plus phentolamine in male erectile dysfunction: a dynamic color power Doppler study. Int J Impot Res. 2000;12(2):134-135. [pmid: 11052645].
Porst H, Giuliano F, Glina S, et al. Evaluation of the Efficacy and Safety of Once-a-Day Dosing of Tadalafil 5 mg and 10 mg in the Treatment of Erectile Dysfunction: Results of a Multicenter, Randomized, Double-Blind, Placebo-Controlled Trial. Eur Urol. 2006;50(2):351-359. [pmid: 16766116].
Pouaha J, Martin S, Reichert-Penetrat S, et al. Thalidomide and sexual dysfunction in men.[comment]. Br J Dermatol. 2002;146(6):1112-1113. [pmid: 12072099].
Power-Smith Parsley. Beneficial sexual side-effects from fluoxetine. Br J Psychiatry Suppl 1994;164 Feb 1994, 249–250. http249–250.
Pratt-Ubunama MN, Nishizaka MK, Calhoun DA. Aldosterone antagonism: An emerging strategy for effective blood pressure lowering. Curr Hypertens Rep. 2005;7(3):186-192. [pmid: 15913492].
Preskorn SH. Duloxetine. Journal of Psychiatric Practice. 2004;10(6):375-385. [pmid: 15583519].
Prins J, Blanker MH, Bohnen AM, et al. Prevalence of erectile dysfunction: A systematic review of population-based studies. Int J Impot Res. 2002;14(6):422-432. [pmid: 12494273].
Pryor J. Vardenafil: update on clinical experience. [Review][10 refs]. Int J Impot Res 2002;14Suppl-9.
Pryor JP. Orgasmic and ejaculatory dysfunction. Sexual & Relationship Therapy. 2002;17(1):87-95.
Qian LX, Wu HF, Xu H, et al. Multi-center Evaluation of Efficacy and Safety of Oral Mesylate Phentolamine for the Treatment of Erectile Dysfunction. Int J Androl. 2001;7(5):302-305.
Quinn MJ, Jefferson K, Persad R. Benign prostatic hyperplasia and sexual dysfunction [3] (multiple letters). Lancet. 2003;361(9368):1562. [pmid: 12737897].
Quirk J, Thornton M, Neumeyer K, et al. Cardiology and vascular disorders. Nat Rev Genet. 2004;3(7 SUPPL.):S12-S17.
Ramasubbu R. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Ramasubbu Rajamannar. Switching to moclobemide to reverse fluoxetine-induced sexual dysfunction in patients with depression. J Psychiatry Neurosci. 1999;24(1):45-50. [pmid: 9987207].
Reffelmann T, Kloner RA. Effects of sildenafil on myocardial infarct size, microvascular function, and acute ischemic left ventricular dilation. Cardiovasc Res. 2003;59(2):441-449. [pmid: 12909327].
Reyes JA, Tan DA, Quimpo JA, et al. The Philippine Male Aging Survey. Aging Male. 2004;7(3):227-235. [pmid: 15669542].
Rhoden EL, Estrada C, Levine L, et al. The value of pituitary magnetic resonance imaging in men with hypogonadism.[see comment]. Br J Urol. 2003;170(3):795-798.
Richardson JD. Intracorporeal injections for the treatment of impotence. Med J Aust. 1991;155(10):688. [pmid: 1943899].
Riley Alan. Oral treatments for erectile dysfunction. Int J STD AIDS. 1996;7(Suppl 3):16-18. [pmid: 8876375].
Riley Alan J, Riley Elizabeth J. Psychological and behavioural aspects of intracavernosal injection therapy for erectile disorder. Sexual & Marital Therapy. 1998;13(3):273-284.
Rizvi K, Hampson JP, Harvey JN. Do lipid-lowering drugs cause erectile dysfunction? A systematic review.[see comment]. [Review] [35 refs]. Fam Pract. 2002;19(1):95-98. [pmid: 11818357].
Roizenblatt S, Guilleminault C, Poyares D, et al. A double-blind, placebo-controlled, crossover study of sildenafil in obstructive sleep apnea. Arch Intern Med. 2006;166(16):1763-1767. [pmid: 16983056].
Rojewski MT, Korper S, Schrezenmeier H. Arsenic trioxide therapy in acute promyelocytic leukemia and beyond: From bench to bedside. Leuk Lymphoma. 2004;45(12):2387-2401. [pmid: 15621751].
Rosano GM, Marazzi G, Patrizi R, et al. Comparison of trimetazidine plus sildenafil to chronic nitrates in the control of myocardial ischemia during sexual activity in patients with coronary artery disease. Am J Cardiol. 2005;95(3):327-331. [pmid: 15670539].
Rose VL. Sildenafil in the treatment of erectile dysfunction. Am Fam Physician. 1998;58(1):268.
Rosen RC, Kostis JB. Overview of phosphodiesterase 5 inhibition in erectile dysfunction. Am J Cardiol. 2003;92(9 SUPPL. 1):9M-18M.
Rosen RC, Lane RM, Menza M. Effects of SSRIs on sexual function: a critical review.[see comment]. [Review] [255 refs]. J Clin Psychopharmacol. 1999;19(1):67-85. [pmid: 9934946].
Rosen Raymond C. Erectile dysfunction: The medicalization of male sexuality. Clin Psychol Rev. 1996;16(6):497-519.
Rosen Raymond C, Leiblum Sandra R. Treatment of male erectile disorder: Current options and dilemmas. Sexual & Marital Therapy. 1993;8(1):5-8.
Rosen Raymond C, Leiblum Sandra, Risa. Erectile disorders: An overview of historical trends and clinical perspectives. Rosen, Raymond C (Ed); Leiblum, Sandra Risa (Ed) 1992;(1992):378
Rosenthal BD, May NR, Metro MJ, et al. Adjunctive use of AndroGel (testosterone gel) with sildenafil to treat erectile dysfunction in men with acquired androgen deficiency syndrome after failure using sildenafil alone. Urology. 2006;67(3):571-574. [pmid: 16527581].
Rowland DL, Greenleaf WJ, Dorfman LJ, et al. Aging and sexual function in men. Arch Sex Behav. 1993;22(6):545-557. [pmid: 8285844].
Rowland DL, Kallan K, Slob AK. Yohimbine, erectile capacity, and sexual response in men. Arch Sex Behav. 1997;26(1):49-62. [pmid: 9015579].
Ruof J, Graf-Morgenstern M, Mnller MJ. Quality of life in patients with erection difficulties: Evaluation of a German version of the "Quality of life measure for men with erection difficulties" (QoL-Med). Aktuel Urol. 2001;32(1):21-26.
Ryder RE, Close CF, Moriarty KT, et al. Impotence in diabetes: aetiology, implications for treatment and preferred vacuum device. Diabet Med. 1992;9(10):893-898. [pmid: 1478032].
Sadock Virginia A. A sexually compulsive male with erectile dysfunction treated with Viagra: Discussion. Journal of Sex Education & Therapy. 1998;23(4):275-277.
Safarinejad MR. Prevalence and risk factors for erectile dysfunction in a population-based study in Iran. Int J Impot Res. 2003;15(4):246-252. [pmid: 12934051].
Sairam K, Kulinskaya E, Boustead GB, et al. Prevalence of undiagnosed prostate cancer in men with erectile dysfunction. BJU Int. 2002;89(3):261-263. [pmid: 11856107].
Sak SC, Eardley I. What is the relationship between benign prostatic hyperplasia and sexual function?. Sexual & Relationship Therapy. 2004;19(4):431-443.
Sakamoto H, Shimada M, Yoshida H. Hemodynamic evaluation of the penile arterial system in patients with erectile dysfunction using power doppler imaging. Urology. 2002;60(3):480-484. [pmid: 12350490].
Saks Bonnie R. A sexually compulsive male with erectile dysfunction treated with Viagra: Case report. Journal of Sex Education & Therapy. 1998;23(4):271-274.
Salonia A, Barbieri L, Chen J, et al. Comparison of the effect of sildenafil and apomorphine SL on nocturnal erections in healthy volunteers: a placebo-controlled study. Eur Urol. 2005;47(4):524-529. [pmid: 15774253].
Salonia A, Maga T, Colombo R, et al. A prospective study comparing paroxetine alone versus paroxetine plus sildenafil in patients with premature ejaculation. Br J Urol. 2002;168(6):2486-2489.
Salonia A, Rigatti P, Montorsi F. Sildenafil in erectile dysfunction: a critical review. Curr Med Res Opin. 2003;19(4):241-262. [pmid: 12841917].
Samarasinghe Y, Rivas-Toro H. HEART UK 18th annual medical and scientific meeting: From diabetes to mixed hyperlipidaemias. British Journal of Cardiology. 2004;11(5):364-365.
Sathe RS, Komisaruk BR, Ladas AK, et al. Naltrexone-induced augmentation of sexual response in men. Arch Med Res. 2001;32(3):221-226. [pmid: 11395188].
Sato Y, Suzuki N, Adachi H, et al. Evaluation of the alleviative action of neurotropin for penile pain associated with intracavernous injection of prostaglandin E1 assessed using the visual analogue scale. Int J Impot Res. 1998;10(1):1-3. [pmid: 9542683].
Savoca G, Silvestre G, Belgrano E. Intracavernosal injection therapy and surgical therapy in diabetic patients with erectile dysfunction. [Review] [26 refs]. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2002;15(1):53-57.
Scalvini T, Martini P R, Obici L et al. Infertility and Hypergonadotropic Hypogonadism as First Evidence of Hereditary Apolipoprotein A-I Amyloidosis. Br J Urol 2007;
Schiavi Raul C, Schanzer Harry, Sozio Giampaolo, et al. Erectile function and penile blood pressure in diabetes mellitus. J Sex Marital Ther. 1994;20(2):119-124. [pmid: 8035468].
Scholz M, Strum S. Re: Recovery of spontaneous erectile function after nerve-sparing radical retropubic prostatectomy with and without early intracavernous injections of alprostadil: results of a prospective, randomized trial.[comment]. Br J Urol. 1999;161(6):1914-1915.
Schrader S, Mills A, Scheperle M, et al. Improvement in sexual functioning and satisfaction in nonresponders to testosterone gel: clinical effectiveness in hypogonadal, HIV-positive males. Clin Cornerstone. 2005;7(Suppl 4):S26-S31. [pmid: 16651205].
Schroder FH, Whelan P, De Reijke TM, et al. Metastatic prostate cancer treated by flutamide versus cyproterone acetate. Final analysis of the "European Organization for Research and Treatment of Cancer" (EORTC) Protocol 30892. Eur Urol. 2004;45(4):457-464. [pmid: 15041109].
Schultheiss D, Stief CG. Physiology and pathophysiology of erection: Consequences for present medical therapy of erectile dysfunction. Andrologia. 1999;31(SUPPL. 1):59-64. [pmid: 10643521].
Schwartz EJ, Wong P, Graydon RJ. Sildenafil preserves intracorporeal smooth muscle after radical retropubic prostatectomy. Br J Urol. 2004;171(2 I):771-774.
Seftel A. Male and female sexual function and dysfunction; andrology. Br J Urol. 2005;174(6):2297-2300.
Seftel A. Effect of lifestyle changes on erectile dysfunction in obese men. A randomized controlled trial. Br J Urol. 2005;173(2):544-545.
Seftel AD. Male and female sexual function and dysfunction; andrology. Br J Urol. 2005;174(4 I):1364-1366.
Segraves RT. Pharmacological enhancement of human sexual behavior. Journal of Sex Education & Therapy. 1991;17(4):283-289.
Segraves R Taylor. Two additional uses for sildenafil in psychiatric patients. [References]. J Sex Marital Ther. 1999;25(4):265-266. [pmid: 10546163].
Segraves Robert, Taylor Segraves, Kathleen Blindt, et al. Sexual function in patients taking bupropion sustained release. Hillside J Clin Psychiatry. 1995;56(8):374.
Seidman Stuart N. Exploring the relationship between depression and erectile dysfunction in aging men. Hillside J Clin Psychiatry. 2002;63(Suppl5):5-12.
Seyam RM, Albakry A, Ghobish A, et al. Prevalence of erectile dysfunction and its correlates in Egypt: a community-based study. Int J Impot Res. 2003;15(4):237-245. [pmid: 12934050].
Shabbir M, Mikhailidis DM, Morgan RJ. Erectile dysfunction: an underdiagnosed condition associated with multiple risk factors.[comment]. Current Medical Research & Opinion. 2004;20(5):603-606. [pmid: 15140326].
Shabbir M, Shah JS, Kirby RS. Cardiac failure and benign prostatic hyperplasia: Management of common comorbidities. BJU Int. 2005;95(3):278-280. [pmid: 15679777].
Shabsigh R. Testosterone therapy in erectile dysfunction. [Review] [34 refs]. Aging Male. 2004;7(4):312-318. [pmid: 15799127].
Shabsigh R. Hypogonadism and erectile dysfunction: The role for testosterone therapy. Int J Impot Res. 2003;15(SUPPL. 4):S9-S13. [pmid: 12934045].
Shakir SAW, Wilton LV, Boshier A, et al. Cardiovascular events in users of sildenafil: Results from first phase of prescription event monitoring in England. Br Med J. 2001;322(7287):651-652. [pmid: 11250850].
Shamloul R, El-Dakhly M, Ghanem H, et al. Intracavernous chlorpromazine versus phentolamine: A double-blind clinical comparative study. Br J Sex Med. 2004;1(3):310-313.
Shamloul R, Ghanem HM, Salem A, et al. The value of penile duplex in the prediction of intracavernous drug-induced priapism. Int J Impot Res. 2004;16(1):78-79. [pmid: 14961063].
Shamsa A, Motavalli SM, Aghdam B. Erectile function in end-stage renal disease before and after renal transplantation. Transplant Proc. 2005;37(7):3087-3089. [pmid: 16213314].
Sharlip ID. Editorial comment. International Braz J Urol. 2005;31(4):354-355.
Sighinolfi MC, de Stefani S, Mofferdin A, et al. Intracavernous prostaglandin E1 infusion in diabetes with associated ischemic necrosis of the glans penis. Br J Urol. 2004;171(6 I):2380.
Silvestri A, Galetta P, Cerquetani E, et al. Report of erectile dysfunction after therapy with beta-blockers is related to patient knowledge of side effects and is reversed by placebo.[see comment]. Eur Heart J. 2003;24(21):1928-1932. [pmid: 14585251].
Singer Carlos, Weiner William J, Sanchez-Ramos J, et al. Sexual function in patients with Parkinson's disease. Journal of Neurology, Neurosurgery & Psychiatry. 1991;54(10):942.
Sipski M, Alexander C, Guo X, et al. Cardiovascular effects of sildenafil in men with SCIs at and above T6. Topics in Spinal Cord Injury Rehabilitation. 2003;8(3):26-34.
Siraj QH, Bomanji J, Akhtar MA, et al. Quantitation of pharmacologically-induced penile erections: The value of radionuclide phallography in the objective evaluation of erectile haemodynamics. Nucl Med Commun. 1990;11(6):445-458. [pmid: 2385430].
Slob AK, Dohle GR, Incrocci L. ‘Sildenafil and pharmaco-penile duplex ultrasonography’ by Speel et al: Inconclusive results. Int J Impot Res. 2002;14(2):136-137. [pmid: 11979331].
Slob A, Koos Steyvers, Christel L, et al. Routine psychophysiological screening of 384 men with erectile dysfunction. J Sex Marital Ther. 1998;24(4):273-279. [pmid: 9805287].
Smith KJ, Roberts MS. The cost-effectiveness of sildenafil. Ann Intern Med. 2000;132(12):933-937. [pmid: 10858175].
Sobh MA, Abd el, Hamid I, et al. Effect of erythropoietin on sexual potency in chronic haemodialysis patients. A preliminary study. Scand J Urol Nephrol. 1992;26(2):181-185. [pmid: 1626208].
Sogari PR, Teloken C, Souto CA. Atropine role in the pharmacological erection test: study of 228 patients. Br J Urol. 1997;158(5):1760-1763.
Sohle GR. Re: The age-related decrease in testosterone is significantly exacerbated in obese men with the metabolic syndrome. What are the implications for the relatively high incidence of erectile dysfunction observed in these men?. Eur Urol. 2007;51(5):1440. [pmid: 17494117].
Sohn Michael, Sikora Richard. Ginkgo biloba extract in the therapy of erectile dysfunction. Journal of Sex Education & Therapy. 1991;17(1):53-61.
Solursh L, Solursh DS. Male erectile disorders in Vietnam combat veterans with chronic post-traumatic stress disorder. International Journal of Adolescent Medicine & Health. 1994;7(2):119-124. [pmid: 22912152].
Solursh Lionel P, Solursh Diane S. Male erectile disorders in Vietnam combat veterans with chronic post-traumatic stress disorder. Int J Adolesc Med Health. 1994;7(2):119-124. [pmid: 22912152].
Sonda LP, Mazo R, Chancellor MB. The role of yohimbine for the treatment of erectile impotence. J Sex Marital Ther. 1990;16(1):15-21. [pmid: 2370671].
Sonksen J, Biering-Sorensen F. Transcutaneous nitroglycerin in the treatment of erectile dysfunction in spinal cord injured. Paraplegia. 1992;30(8):554-557. [pmid: 1522996].
Sorbera LA, Martin L, Rabasseda X, et al. Vardenafil. Treatment of erectile dysfunction. Phosphodiesterase 5 inhibitor. Drugs of the Future. 2001;26(2):141-144.
Sparwasser C, Drescher P, Pust RA, et al. Long-term results of therapy with intracavernousal injections and penile venous surgery in chronic erectile dysfunction. Scand J Urol Nephrol Suppl. 1994;157(Suppl):107-112. [pmid: 7939440].
Speakman MT, Kloner RA. Viagra and cardiovascular disease. Journal of Cardiovascular Pharmacology & Therapeutics. 1999;4(4):259-267. [pmid: 10684547].
Srilatha B, Adaikan PG, Chong YS. Relevance of oestradiol-testosterone balance in erectile dysfunction patients' prognosis. Singapore Med J. 2007;48(2):114-118. [pmid: 17304389].
Stas SN, Anastasiadis AG, Fisch H, et al. Urologic aspects of andropause. Urology. 2003;61(2):261-266. [pmid: 12597927].
Steers WD. Tachyphylaxis and phosphodiesterase type 5 inhibitors.[comment]. Br J Urol. 2002;168(1):207.
Steers WD. Viagra - After one year. Urology. 1999;54(1):12-17. [pmid: 10414719].
Steidle C, Witt MA, Matrisciano J, et al. Sexual functioning and satisfaction in nonresponders to testosterone gel: Potential effectiveness of retreatment in hypogonadal males. Clin Cornerstone. 2005;7(Suppl 4):S20-S25. [pmid: 16651204].
Steiger A, Holsboer F, Benkert O. Studies of nocturnal penile tumescence and sleep electroencephalogram in patients with major depression and in normal controls. Acta Psychiatr Scand. 1993;87(5):358-363. [pmid: 8517177].
Steiger Axel, Benkert O, Holsboer F. Effects of long-term treatment with the MAO-A inhibitor moclobemide on sleep EEG and nocturnal hormonal secretion in normal men. Neuropsychobiology. 1994;30(23):101-105. [pmid: 7800155].
Stief CG, Uckert S, Becker AJ, et al. The effect of the specific phosphodiesterase (PDE) inhibitors on human and rabbit cavernous tissue in vitro and in vivo. Br J Urol. 1998;159(4):1390-1393.
Stolk EA, Busschbach JJ, Caffa M, et al. Cost utility analysis of sildenafil compared with papaverine-phentolamine injections.[see comment]. BMJ. 2000;320(7243):1165-1168. [pmid: 10784537].
Strachan MW, Teoh WL, Don-Wauchope AC, et al. Clinical and radiological features of patients with macroprolactinaemia. Clin Endocrinol (Oxf). 2003;59(3):339-346. [pmid: 12919157].
Struthers AD. Aldosterone blockade in heart failure. J Renin Angiotensin Aldosterone Syst. 2004;5(SUPPL. 1):S23-S27. [pmid: 15526239].
Suetomi T, Endo F, Takeshima H, et al. Evaluation of the effectiveness of sildenafil using questionnaire methods versus audio-visual sexual stimulation. Int J Urol. 2005;12(4):369-373. [pmid: 15948724].
Suzuki F, Shimizu C, Umetsu M, et al. Adult-onset idiopathic hypogonadotropic hypogonadism due to isolated pituitary gonadotropin deficiency. Adv Intern Med. 2004;43(7):571-574.
Svartberg J, Aasebo U, Hjalmarsen A, et al. Testosterone treatment improves body composition and sexual function in men with COPD, in a 6-month randomized controlled trial. Respir Med. 2004;98(9):906-913. [pmid: 15338805].
Swartz DA, Todd MW. Intracavernous papaverine and glaucoma.[see comment]. JAMA. 1990;264(5):570. [pmid: 2366292].
Szucs A, Janszky J, Barsi P, et al. Sleep-related painful erection is associated with neurovascular compression of basal forebrain [5]. J Neurol. 2002;249(4):486-487. [pmid: 11967660].
T'Sjoen G, Feyen E, De Kuyper P, et al. Self-referred patients in an aging male clinic: much more than androgen deficiency alone. Aging Male. 2003;6(3):157-165. [pmid: 14628496].
Tarhan F, Canguven O, Kuyumcuoglu U. Intracavernous sodium nitroprusside (SNP) versus papaverine/phentolamine in erectile dysfunction: a comparative study of short-term efficacy and side-effects.[comment]. Br J Sex Med. 2006;3(2):377.
Tarhan F, Kuyumcuoglu U, Kolsuz A, et al. Effect of intracavernosal sodium nitroprusside in impotence. Urol Int. 1996;56(4):211-214. [pmid: 8776816].
Tas A, Dilek K, Gullulu M et al. Treatment of erectile dysfunction in hemodialysis patients and effects of sildenafil [abstract]. XXXVIII Congress of the European Renal Association European Dialysis & Transplant Association June 24–27 2003;2001, Vienna, Austria 131p. 2003.
Teillac P, Bono AV, Irani J, et al. The role of luteinizing hormone-releasing hormone therapy in locally advanced prostate cancer and biochemical failure: Considerations for optimal use. Clin Ther. 2005;27(3):273-285. [pmid: 15878381].
Teloken PE, Smith EB, Lodowsky C, et al. Defining association between sleep apnea syndrome and erectile dysfunction. Urology. 2006;67(5):1033-1037. [pmid: 16698364].
Thadani U, Smith W, Nash S, et al. The effect of vardenafil, a potent and highly selective phosphodiesterase-5 inhibitor for the treatment of erectile dysfunction, on the cardiovascular response to exercise in patients with coronary artery disease. J Am Coll Cardiol. 2002;40(11):2006-2012. [pmid: 12475462].
Thaveundayil JX, Hambalek R, Ng Ying, et al. Prolonged penile erections induced by hydroxyzine: Possible mechanism of action. Neuropsychobiology. 1994;30(1):4-6. [pmid: 7969858].
Thrasher JB. What's new in urology. J Am Coll Surg. 2005;201(3):438-448. [pmid: 16125079].
Tindall B, Forde S, Goldstein D, et al. Sexual dysfunction in advanced HIV disease. AIDS Care. 1994;6(1):105-107. [pmid: 8186272].
Tomlinson J. Viagra and its use in cardiovascular disease.[erratum appears in J Hum Hypertens 2000 Apr;14(4):283]. [Review] [11 refs]. J Hum Hypertens. 1999;13(9):593-594. [pmid: 10482968].
Tomova A, Kumanov P. Are dehydroepiandrosterone sulphate and lipids associated with erectile dysfunction? [References]. Maturitas. 2005;50(4):294-299. [pmid: 15780529].
Tordjman G. NO/Pg E1: a new association in the treatment of erectile impotence. Contracept Fertil Sex (Paris) 1993;.21, pp.509–510, 1993.
Traish AM, Goldstein I, Kim NN. Testosterone and erectile function: from basic research to a new clinical paradigm for managing men with androgen insufficiency and erectile dysfunction. Eur Urol. 2007;52(1):54-70. [pmid: 17329016].
Trinchieri A, Nicola M, Masini F, et al. Prospective comprehensive assessment of sexual function after retropubic non nerve sparing radical prostatectomy for localized prostate cancer. Arch Ital Urol Androl. 2005;77(4):219-223. [pmid: 16444937].
Truss MC, Becker AJ, Djamilian MH, et al. Role of the nitric oxide donor linsidomine chlorhydrate (SIN-1) in the diagnosis and treatment of erectile dysfunction. Urology. 1994;44(4):553-556. [pmid: 7941195].
Tsai SK, Hong CY. Intracavernosal metaraminol for treatment of intraoperative penile erection. Postgrad Med J. 1990;66(780):831-833. [pmid: 2099422].
Tsujimura A, Matsumiya K, Matsuoka Y, et al. Bioavailable testosterone with age and erectile dysfunction. Br J Urol. 2003;170(6 Pt 1):2345-2347.
Tuzgen S, Karamehmetoglu SS, Karacan I, et al. Use of sildenafil in the treatment of erectile dysfunction in patients with spinal cord injury. Neurosurgery Quarterly. 2006;16(1):40-43.
Tzivoni D, Klein J, Hisdai D, et al. The Israel Heart Society expert consensus document: The cardiac patient and sexual activity in the era of sildenafil (Viagra). Israel Medical Association Journal: Imaj. 2000;2(1):63-65. [pmid: 10892379].
Unnikrishnan AG, Rajaratnam S, Seshadri MS, et al. The ‘hook effect’ on serum prolactin estimation in a patient with macroprolactinoma. Neurol India. 2001;49(1):78-80. [pmid: 11303248].
Uygur MC, Arik AI, Altug U, et al. Effects of the 5 alpha-reductase inhibitor finasteride on serum levels of gonadal, adrenal, and hypophyseal hormones and its clinical significance: a prospective clinical study. Steroids. 1998;63(4):208-213. [pmid: 9589555].
Valdevenito R, Melman A. Intracavernous self-injection pharmacotherapy program: analysis of results and complications. Int J Impot Res. 1994;6(2):81-91. [pmid: 7951702].
van Basten JP, Van Driel MF, Hoekstra HJ, et al. Erectile dysfunction with chemotherapy.[comment]. Lancet. 2000;356(9224):169. [pmid: 10963279].
van Basten JP, Van Driel MF, Hoekstra HJ, et al. Erectile dysfunction with chemotherapy. Lancet. 2000;356(9224):169. [pmid: 10963279].
Van Ahlen H, Peskar BA, Sticht G, et al. Pharmacokinetics of vasoactive substances administered into the human corpus cavernosum. Br J Urol. 1994;151(5):1227-1230.
Van Moorselaar J. LUTS and Sexual Dysfunction: Implications for Management of BPH. European Urology Supplements. 2003;2(10):13-20.
Vatansever HS, Kayikcioglu O, Gumus B. Histopathologic effect of chronic use of sildenafil citrate on the choroid & retina in male rats. Indian J Med Res. 2003;117(MAY):211-215. [pmid: 14609049].
Verit A, Oguz H. Ophthalmic aspects of erectile dysfunction drugs [3]. Am J Ophthalmol. 2006;141(3):598. [pmid: 16490529].
Vick RN, Benevides M, Patel M, et al. The efficacy, safety and tolerability of intracavernous PNU-83757 for the treatment of erectile dysfunction. Br J Urol. 2002;167(6):2618-2623.
Vickers MA, Wright EA. Erectile dysfunction in the patient with diabetes mellitus. Am J Manag Care. 2004;10(1 SUPPL.):S3-S11. [pmid: 14974584].
Vidal J, Curcoll L, Roig T, et al. Intracavernous pharmacotherapy for management of erectile dysfunction in multiple sclerosis patients. Rev Neurol. 1995;23(120):269-271. [pmid: 7497173].
Vinik AI, Maser RE, Mitchell BD, et al. Diabetic autonomic neuropathy. [Review] [192 refs]. Diabetes Care. 2003;26(5):1553-1579. [pmid: 12716821].
Virag R, Floresco J, Richard C. Impairment of shear-stress-mediated vasodilation of cavernous arteries in erectile dysfunction. Int J Impot Res. 2004;16(1):39-42. [pmid: 14963469].
Vlachopoulos C, Hirata K, O'Rourke MF. Effect of sildenafil on arterial stiffness and wave reflection. Vasc Med. 2003;8(4):243-248. [pmid: 15125484].
Vogt HJ, Brandl P, Kockott G, et al. Double-blind, placebo-controlled safety and efficacy trial with yohimbine hydrochloride in the treatment of nonorganic erectile dysfunction. Int J Impot Res. 1997;9(3):155-161. [pmid: 9315493].
Wagner G, Mulhall J. Pathophysiology and diagnosis of male erectile dysfunction. BJU International - Supplement. 2001;88(3):3-10.
Wagner G, Rabkin J, Rabkin R. Effects of testosterone replacement therapy on sexual interest, function, and behavior in HIV+ men. J Sex Res. 1997;34(1):27-33.
Wagner Gorm, Kaplan Helen, Singer. The new injection treatment for impotence: Medical and psychological aspects. Refuat Hapeh Vehashinayim 1993;x, 210 pp. Philadelphia, PA, US210
Wald M, Seftel AD, Ross LS, et al. Computational models for detection of erectile dysfunction. Br J Urol. 2005;173(1):167-170.
Waldbaum RS. The safety of PDE5 inhibitors in ED treatment: Putting cardiovascular concerns to rest. Cardiology Review. 2005;22(9):23-24.
Wang ZL, Shao SX, Li B, et al. Sildenafil versus prostaglandin E1 in the management of erectile dysfunction. Journal of Clinical Urology. 2002;17(7):347-349.
Wang Z, Liu BC, Chen B, et al. Randomized controlled study on erectile dysfunction treated by trazodone. Chinese Journal of Andrology. 2002;16(3):236-238.
Ware J, Catesby Rose F, Vincent McBrayer, et al. The acute effects of nefazodone, trazodone and buspirone on sleep and sleep-related penile tumescence in normal subjects. Sleep: Journal of Sleep Research & Sleep Medicine. 1994;17(6):544-550.
Watanabe T, Chancellor MB, Rivas DA, et al. Epidemiology of current treatment for sexual dysfunction in spinal cord injured men in the USA model spinal cord injury centers. J Spinal Cord Med. 1996;19(3):186-189. [pmid: 8819027].
Webb DJ, Muirhead GJ, Wulff M, et al. Sildenafil citrate potentiates the hypotensive effects of nitric oxide donor drugs in male patients with stable angina. J Am Coll Cardiol. 2000;36(1):25-31. [pmid: 10898408].
Wegner HEH, Knispel HH, Meier T, et al. Nitric oxide donor, linsidomine chlorhydrate (SIN-1), in the diagnosis and treatment of erectile dysfunction: Critical appraisal and review of the literature. International Urology & Nephrology. 1995;27(5):621-628. [pmid: 8775048].
Weinhardt LS, Carey MP. Prevalence of erectile disorder among men with diabetes mellitus: Comprehensive review, methodological critique, and suggestions for future research. J Sex Res. 1996;33(3):205-214.
Weinsaft JW, Hickey K, Bokhari S, et al. Effects of tadalafil on myocardial blood flow in patients with coronary artery disease. Coron Artery Dis. 2006;17(6):493-499. [pmid: 16905960].
Weiske WH. Invasive diagnosis and therapy - Are they still reasonable in the age of sildenafil?. Andrologia. 1999;31(SUPPL. 1):95-97. [pmid: 10643526].
Wespes E, Rammal A, Garbar C. Sildenafil non-responders: haemodynamic and morphometric studies. Eur Urol. 2005;48(1):136-139. [pmid: 15967263].
Wessells H, Fuciarelli K, Hansen J, et al. Synthetic melanotropic peptide initiates erections in men with psychogenic erectile dysfunction: double-blind, placebo controlled crossover study. Br J Urol. 1998;160(2):389-393.
Wessells H, Gralnek D, Dorr R, et al. Effect of an alpha-melanocyte stimulating hormone analog on penile erection and sexual desire in men with organic erectile dysfunction. Urology. 2000;56(4):641-646. [pmid: 11018622].
Wheatley D. Triple-blind, placebo-controlled trial of Ginkgo biloba in sexual dysfunction due to antidepressant drugs. Hum Psychopharmacol. 2004;19(8):545-548. [pmid: 15378664].
Wilke DR, Parker C, Andonowski A, et al. Testosterone and erectile function recovery after radiotherapy and long-term androgen deprivation with luteinizing hormone-releasing hormone agonists. BJU Int. 2006;97(5):963-968. [pmid: 16542340].
Williams T, Honeywell M, Branch E et al. Tadalafil in the treatment of erectile dysfunction. P & T 2004;29(5):
Wilt TJ, Fink HA. Is antidepressant plus sildenafil a recipe for priapism?. Postgrad Med. 2004;116(6):11-12. [pmid: 15620123].
Witt Deborah K. Yohimbine for erectile dysfunction. J Fam Pract. 1998;46(4):282-283. [pmid: 9564368].
Wood P L. Slow, tedious but essential: The need for incremental R&D. Current Drug Discovery 2004;(pp 31–35):-35.
Wyllie MG. The hunt for pink Viagra. BJU Int. 2005;95(1):181-182. [pmid: 15638919].
Wyllie MG. Let's hope for more in 2004. BJU Int. 2004;93(1):175-176. [pmid: 14678392].
Wyllie MG. The Second International Consultation on Erectile Dysfunction: Highlights from the pharmaceutical industry. BJU Int. 2003;92(6):645-646. [pmid: 14511053].
Wyllie MG. The genesis of a phytopharmaceutical industry (Mark II). BJU Int. 2003;91(7):721-722. [pmid: 12699492].
Yajima T, Yajima Y, Koppiker N, et al. No clinically important effects on intraocular pressure after short-term administration of sildenafil citrate (Viagra). Am J Ophthalmol. 2000;129(5):675-676. [pmid: 10844068].
Yaman O, Akand M, Gursoy A, et al. The effect of diabetes mellitus treatment and good glycemic control on the erectile function in men with diabetes mellitus-induced erectile dysfunction: a pilot study. Br J Sex Med. 2006;3(2):344-348.
Yamanaka M, Shirai M, Shiina H, et al. Vascular endothelial growth factor restores erectile function through inhibition of apoptosis in diabetic rat penile crura. Br J Urol. 2005;173(1):318-323.
Yan JY, Yang WZ. A comparative effects of Sildenafil and Yohimbine for the treatment of erectile dysfunction. Chinese Journal of Andrology. 2000;14(2):103-105.
Yarkony GM. Enhancement of sexual function and fertility in spinal cord-injured males. [Review] [40 refs]. Am J Phys Med Rehabil. 1990;69(2):81-87. [pmid: 2184843].
Yassin AA, Saad F. Treatment of sexual dysfunction of hypogonadal patients with long-acting testosterone undecanoate (Nebido). [Review] [25 refs]. World J Urol. 2006;24(6):639-644. [pmid: 17048032].
Yassin AA, Saad F. Dramatic improvement of penile venous leakage upon testosterone administration. A case report and review of literature. Andrologia. 2006;38(1):34-37. [pmid: 16420241].
Yasumoto R, Nishisaka N, Sakakura T, et al. Ethanol embolization for impotent patients with venous leakage: A new technique and initial results. Minimally Invasive Therapy & Allied Technologies: Mitat. 1996;5(6):564-566.
Yeager J, Beihn RM. Retention and migration of alprostadil cream applied topically to the glans meatus for erectile dysfunction. Int J Impot Res. 2005;17(1):91-95. [pmid: 15538395].
Youssef AF, Fort FL, Ronsen B, et al. Evaluation of apomorphine HCl effects on reproductive endpoints: Studies in male rats and dogs. J Toxicol Sci. 1999;51(2):273-279.
Zaslau S, Nicolis C, Galea G, et al. A simplified pharmacologic erection program for patients with spinal cord injury. J Spinal Cord Med. 1999;22(4):303-307. [pmid: 10751135].
Zasler ND. Therapeutic approaches to sexual impotence. Hospital Practice (Office Edition). 1988;23(7):197-200.
Zhao L. Clinical observation on the therapeutic effects of heavy moxibustion plus point-injection in treatment of impotence. J Tradit Chin Med. 2004;24(2):126-127. [pmid: 15270266].
Zhigang Long, Xiaowei Liu, Shengbo Lu. Therapy of impotence with traditional Chinese medicine. Journal of Sex Education & Therapy. 1994;20(2):140-143.
Zini Dante, Carani Cesare, Baldini Augusto, et al. Sexual behavior of men with isolated hypogonadotropic hypogonadism or prepubertal anterior panhypopituitarism. Horm Behav. 1990;24(2):174-185. [pmid: 2365300].
Zusman RM. Cardiovascular data on sildenafil citrate: introduction.[erratum appears in Am J Cardiol 1999 Jul 15;84(2):244]. Am J Cardiol. 1999;83(5A):1C-2C. [pmid: 10073775].
Zusman RM, Prisant LM, Brown MJ. Effect of sildenafil citrate on blood pressure and heart rate in men with erectile dysfunction taking concomitant antihypertensive medication. Sildenafil Study Group. J Hypertens. 2000;18(12):1865-1869. [pmid: 11132612].