# Appendix C. Evidence Tables

Evidence Table C1. Oral Sildenafil

Author Funding | N; study design; eligibility | Participants characteristics | Diagnosis details | Intervention | Outcomes
Abdel-Naser (2004) ^1^ Funding source: Pfizer | N screened = NR N randomized = 30 IG1, n = 15 IG2, n = 15 CG, n = 12 (normal men) Intention to treat (ITT) analysis: NR Inclusion: men with psychogenic ED (no response to sildenafil citrate of up to 100 mg in more than one occasion within a one mo); also non-sildenafil treated pts with ED served as control Exclusion: penile anatomical defects, active peptic ulcer, bleeding dx, retinitis pigmentosa, major haematological renal or hepatic abnormalities; hx of stroke or recent MI; loss of libido; use of anihypertensives, nitrates, tranquilizers or drugs known to interfere with sildenafil citrate metabolism (e.g. cimetadine & ketoconazol) | Age, mean (sd): 42.5 (6.7) y, range 34–58 y Race (%): NR Co-morbidities: NR Previous ED treatment: 100% with Sidenafil, 100 mg Smoking status: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: 100% Physiologic ED: 0 Mixed ED: 0 | IG1: sildenafil citrate (night 3) & placebo (nights 1,2 & 4) IG2: sildenafil citrate (night 4) & placebo (nights 1, 2, & 3) CG: placebo (all nights) IG1: Dose: 50 mg Duration: 4 nights Frequency: once, 1 hr before bedtime/night Compliance (%): NR IG2: Dose: as IG Duration: 4 nights Frequency: as IG Compliance (%): NR CG: Dose: NA Duration: 4 nights Frequency: once/night Compliance (%): NR Run In period: NR Wash out period: NR F/u duration: NR | Primary outcome results: NPTR for basal condition, mean (sd) placebo nights vs. sildenafil night Number of events IG1 4.7 (1.4) vs. 6.7 (1.6) IG2: 3.8 (1.2) vs. 7 (1.2) Total event duration, hr: IG: 1.4 (0.2) vs. 2.1 (0.4) IG2: 1.3 (0.2) vs. 2.4 (0.2) Tip rigidity IG1: 39.7 (9.5) vs. 47.8 (10.4) IG2: 44.3 (10.3) vs. 57.6 (10.7) Base rigidity: IG1: 45.1 (8.8) vs. 57.3 (10.5) IG2: 49.4 (10.5) vs. 60.8 (11) Other outcomes assessed: base, tip RAU, and TAU (result suggestive of possible performance anxiety effect in this population); no result reported for CG Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE, n (%): 3 (10), headache in 2 pts (6.7%), GI upset in 1 (3.3%) SAE: 0 Ascertainment of outcomes assessed: RigiScan nocturnal penile tumescence and rigidity (NPTR); RAU and TAU
Albuquerque (2005) ^2^ Funding source: Pfizer | N screened = 153 N randomized = 120 IG, n = 61 CG, n = 59 ITT analysis used for primary outcome: yes (n=120) Inclusion: men 18 y or older, with established ED of at least 6 mo duration, in a stable sexual relationship for 6 mo, and with hypertension that is being treated with at lest 2 drugs. (Diuretics, alpha-blocker, beta blockers, ACE inhibitors or calcium blockers); baseline IIEF score of 25 or less Exclusion: Concurrent tx with nitrates, presence of genital deformity or sexual disturbance that precluded sexual intercourse, use of any form of ED tx within 4 wks, alcohol or drug abuse, presence of retinitis pigmentosa, major medical condition or inability to fill out log or comply with study | Age, mean (range): 30–81y Race: Brazilian Co-morbidities: None Previous ED treatment: None Smoking status n (%): 13 (21.3) vs. 15 (25.4) Body weight: NR | Concomitant medications: None Duration of ED, median (range): 2.0 (0.6 – 24) vs. 2.3 (0.6 –30) Underlying disease: hypertension (duration 0.6 –30 y) Psychogenic ED, n (%): 9 (14.8) vs. 7 (11.9) Physiologic ED, n (%): 11 (18) vs. 11 (18.6) Mixed ED, n (%): 41 (67.2) vs. 41 (69.5) Other, n (%): alcohol use 30 (49.2) vs. 30 (50.2) | IG: Sildenafil CG: Placebo IG: Dose: 50mg (adjusted to 25 or 100mg) Duration: 8wks Frequency: 1 hr before sexual intercourse Compliance n (%): 46 (75.4) CG: Dose: NA Duration: 8 wks Frequency: 1 hr before sexual intercourse Compliance n (%): 41 (69.5) Run In period: None Wash out period: 4 wks F/u duration: 2, 4 and 8 wks Other: % pts taking 25 mg: 6.6 vs. 5.1 50 mg: 39.3 vs. 74.6 100 mg: 54.1 vs. 20.3 | Primary outcome results: IIFE, mean (sd): (mean baseline/Q=2) Q1: 4.2 (1.3) vs. 2.6 (1.5) Q3: 4 (1.3) vs. 2.6 (1.6) Q4: 4 (1.4) vs. 2.2 (1.6) Q5: 4.2 (1.2) vs. 2.6 (1.5) Q15: 3.6 (1.0) vs. 2.4 (1.1) Q6: 4.2 (1.3) vs. 3.4 (1.4) Q7: 4.2 (1.2) vs. 2.3 (1.4) GEQ, % improved: (87) vs. (37) Successful intercourse attempts wks 2, 4 and 8 (%): 54, 61, 73 vs. 13, 20, 29 Other outcomes assessed: EDITS Withdrawals/drop-outs/loss to f/u, n (%): 22 (18.3) WDAE: tx interrupted 1 (1.4) vs. 2 (3.4) TAE, n (%): in 2% or more 35 (57.3) vs. 16 (27.1); including facial flushing 8 (13) vs. 2 (3.4); headache 7 (11.4) vs. 2 (3.4); rhinitis 6 (9.8) vs. 1 (1.7); dyspepsia 4 (6.5) vs. 0; dizziness= abdominal pain 2 (3.2) vs. 1 (1.7); paresthesia 1 (1.6) vs. 0; hypertension 1 (1.6) vs. 3 (5.1); chest pain 1 (1.6) vs. 2 (3.4); flue like syndrome= diarrhea 1 (1.6) vs. 2 (3.); AE in 82% vs. 40% of pts SAE: 3 (5) vs. 1 (1.7); CVA, pulmonary edema/heart failure, atrial fibrillation/arrhythmia, and one polytrauma due to MVA leading to death) Ascertainment of outcomes assessed: IIEF, patient logs, EDITIS, GEQ
Althof (2006) ^3^ Funding source: Pfizer Inc. | N screened = NR N randomized = 553 (combined from two studies US, n=253; Brazil, Mexico, Australia and Japan n=300) IG, n = 274 CG, n = 279 ITT analysis used for primary outcome: yes Inclusion: men 18 or older with documented ED (score of 21 or less on IIEF) Exclusion: BP of 90 mmHg or less or 170/110 mmHg or more; sign cardiac dx; use of nitrates, nitric oxide donors, or ritonavir; more than 6 dosed of sildenafil within 6 mo prior to study entry | Age, mean (sd): 56 (11) vs. 55 (12) y Race: White 55.5%; Black 15%; Asian 5.5%; Other 23.5% Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight, mean (sd): 86 (16) vs. 85 (16) kg | Concomitant medications, n (%): Duration of ED, mean (sd): 4.4 (4.5) vs. 4.3 (4.4) y Underlying disease, n (%): Not specific Psychogenic ED, n (%): 44 (16) vs. 55 (20) Physiologic ED, n (%): 119 (43) vs. 113 (41) Mixed ED, n (%): 116 (41) vs. 106 (39) | IG: Sildenafil CG: Placebo IG: Dose: NR Duration: 12 wks Frequency: NR Compliance: NR CG: Dose: NA Duration: NR Frequency: NR Compliance: NR Run In period: NR Wash out period: NR F/u duration: 12 wks (f/u intervals at 2, 4, 6, 8 wks) | Primary outcome results: IIEF, LS mean change from baseline (SE) EF: 11.0 (0.5) vs. 4.8 (0.5), p<0.001 OF: 2.5 (0.2) vs. .0 (0.2), p<0.001 SD: 1.3 (0.1) vs. 0.6 (0.1), p<0.001 IcS: 5.2 (0.2) vs. 2.9 (0.2), p<0.001 OS: 3.8 (0.2) vs. 1.7 (0.2), p<0.001 Successful sexual attempts, mean change %(sd): 59 (2.6) vs. 39 (42) GEQ, frequency of achieved erections at end of tx: 3.9 (1.5) vs. 2.7 (1.6), p<0.001 Other outcomes assessed: SEAR sexual relationship domain (sign more improved in IG) Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): 3 (1) vs. 1 (0.4) TAE, n (%): 129 (46) vs. 88 (32); included headache, flushing, dyspepsia, and rhinitis SAE, n (%): 1 (<1) vs. 1 (<1); one case of coronary artery disease in sildenafil grp and one case of urinary tract infection in placebo Ascertainment of outcomes assessed: SEAR; self-esteem, confidence and sexual relationship satisfaction; IIEF, GEQ, self reported event log
Bank (2006) ^4^ Funding source: Pfizer Inc. (educational grant) | N screened = NR N randomized = NR (n=35 completed the trial) IG1, n = 12 IG2, n = 10 CG, n = 13 ITT analysis used for primary outcome: NR Inclusion: men 25–75 y, in a stable relationship, and normal libido, IIEF-5 < 21, with current use of sildenafil (evaluated after the 2–4 wks run in period tx with 100 mg sildenafil); with vasculogenic ED Exclusion: use of lipid lowering agents, angiotensin converting enzyme inhibitors, anti-depressants or nitrates; hx of prostate cancer or pelvic/ low back surgery | Age, mean (SEM): 59.2 (1.9) vs. 58.7 (3.3) vs. 63.8 (2.1) y Race: NR Co-morbidities, n (%): DM type II, 2 (5) only in CG Previous ED treatment: NR Smoking status: 3 (9%); one in each grp Body weight: NR Other: BMI, mean (SEM) 27.5 (1.5) vs. 29.7 (2.3) vs. 26.1 (0.9) kg/m^2^ | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): vasculogenic Psychogenic ED, n (%): NR Physiologic ED, n (%): 100% Mixed ED, n (%): NR Other: lipid profiles reported, SBP; CBP; total cholesterol; LDL-c; HDL-c; TG, and CRP | IG1: Sildenafil + Atorvastatin IG2: Sildenafil + quinapril CG: Sildenafil + placebo IG1: Dose: 100 mg sildenafil + 40 mg atrovastatin Duration: 3 mo Frequency: sildenafil as instruction; atrovastatin once/d Compliance: NR IG2: Dose: 100 mg sildenafil + 10 mg quinapril Duration: 3 mo Frequency: as IG1 Compliance: NR CG: Dose: sildenafil as IG Duration: 3 mo Frequency: as IG Compliance: NR Run In period: 2–4 wks on 100 mg sildenafil Wash out period: NA F/u duration: 3 mo | Primary outcome results: Mean (SEM) baseline vs. post tx IIEF-5 IG1: 11.1 (1.5) vs. 16.7 (2.0) IG2: 9.9 (1.1) vs. 18.7 (2.2) CG: 10.2 (1.6) vs. 11.3 (2.1) IIEF-EF domain: IG1: 14.5 (2.2) vs. 20.8 (2.3) IG2: 13.8 (1.3) vs. 23.6 (2.3) CG: 12.8 (2.0) vs. 14.2 (2.5) N of intercourse attempts/3 mo, mean (SEM): IG1, 37.7 (12) vs. IG2, 22.5 (7.7) vs. IG3, 23.8 (13.9) Other outcomes assessed: NS differences between IG1/2 and CG for penile blood flow and vascular function, PSV, EDV, RI, and FMD; no differences for SBP, DBP, HDL-c and CRP, no correlation between IIEF scores and improvement on other measures Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: IIEF-5;Penile Doppler studies
Bawa (2004) ^5^ Funding source: NR | N screened = NR N randomized = 59 crossover design IG/ CG, n = 59 ITT analysis used for primary outcome: NR Inclusion: Indian men with ED for 6 mo or longer Exclusion: NR | Age, mean (range): 32.8 (18–60) y Race: Asian (India) Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 23 (6–120) mo Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: sildenafil CG: placebo IG: Dose: 50 mg Duration: 3 wks Frequency: NR Compliance (%): NR CG: Dose: N/A Duration: 3 wks Frequency: NR Compliance (%): NR Run In period: NR Wash out period: NR F/u duration: 1 y | Primary outcome (EF): IIEF score, mean (SEM) EF domain Baseline: 18.5 (0.7) post tx: 25.6 (0.7) vs. 22.1 (0.7), P<0.05 Intercourse satisfaction: Baseline 8.2 (0.4) post tx: 11.9 (0.4) vs. 10 (0.4), not sign OF: baseline: 7.3 (0.3) post tx: 8.8 (0.2) vs. 7.9 (0.3), p<0.05 SD: Baseline: 6.9 (0.1) post tx: 7.1 (0.1) vs. 6.9 (0.2), not sign OS: pre tx: 5.8 (0.2) post tx: 7.0 (0.2) vs. 6.4 (0.2), p<0.05 GAQ (% improved): 81.3% vs. 28.8% (P<0.001) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: NR WDAE: 0 TAE: 4 (6.8%) vs. 3.4% including Headache 30.2%; Flushing: 43.5%; Dyspepsia: 18.8%; Dizziness: 7.5% SAE: 0 Ascertainment of outcomes assessed: IIEF; partner questionnaire
Becher (2002) ^6^ Funding source: Pfizer | N screened = 156 N randomized = 143 IG, n = 72 CG, n = 71 ITT analysis used for primary outcome: NR Inclusion: Men with ED who were in a stable relationship with a female partner of at least 6 mo Exclusion: penile anatomical defects, primary diagnosis of another sexual disorder, SCI, any major psychiatric disorder not well controlled, poorly controlled DM, Hx of alcohol or substance abuse, major haematological, renal or hepatic abnormalities, hypotension or malignant hypertension, recent stroke or myocardial infraction or if they were receiving nitrated. | Age, mean (sd); 57.2 (11.5) vs. 56.7 (10.9) y Race, n (%): White Southern Latin 6 (8.3) vs. 7 (9.8) Hispanic: 66 (91.7) vs. 64 (90.2) Co-morbidities: NR Previous ED treatment: NR Smoking status, n (%): Current: 32 (44.4) vs.27 (38.0) Former: 28 (38.9) vs. 26 (36.6) Body weight, mean (sd): 84.2 (11.8) vs. 83.4 (14.2) | Concomitant medications, n (%): Any medication 51 (70.8) vs. 51 (71.8), with no sign difference between grps for use of any medication Duration of ED, mean (range): 3.5 (0.5–22.4) vs. 2.6 (0.5–20.5) y Underlying disease (diagnosis), n (%): Diabetes: 12 (16.6) vs. 13 (18.3) Hypertension: 23 (31.9) vs. 28 (43.6) Psychogenic ED: 44.3% Physiologic ED: 39.3% Mixed ED: 16.4% | IG: Sildenafil CG: Placebo IG: Dose: 25–50 and 100mg tablets Duration: 12 wks Frequency: 1h before planned sexual activity, up to once/d Compliance: 90% CG: Dose: NA (14 tablets/bottle as IG) Duration: 12 wks Frequency: as IG Compliance: 89% Run In period: 4 wks Wash out period: None F/u duration: 12 wks (2, 4, 8, and 12 wks) | Primary outcome results: IIEF mean (SE): % Change, Q3: 3.8 (0.17) (66.2) vs. 2.7 (0.18) (15.1) % Change Q4: 3.6 (0.18) (77.6) vs. 2.5 (0.18) (21.2) EF: 20.5 (0.6) vs. 15.9 (0.7) OF: 8.2 (0.35) vs. 7.0 (0.37) S-D: 7.68 (0.18) vs. 7.0 (0.19) GEQ, % with Improved erections: (77.3) vs. (33.8) Other outcomes assessed: all IIEF questions (1–15) Withdrawals/drop-outs/loss to f/u, n (%): 3 (2) vs. 2 (3) WDAE, n (%): 7 (9.7) vs. 6 (8.5) discontinued treatment TAE, n (%): pts with AE 45 (59.1) vs. 21 (29.6) Flushing: 16 (22.2) vs. 3 (4.2); Headache: 17 (23.6) vs. 6 (8.4); Hypertension: 1 (1) vs. 3 (4); nasal congestion 2 (2.3) vs. 1 (1); tachycardia 3 (4) vs. 0 SAE: 2 (2.8) vs. 1 (1.4) died in due to MI Ascertainment of outcomes assessed: RigiScan test (nocturnal penile tumescence NPT), IIEF (q3 and 4) (investigator), GEAQ, self and partner reported event logs
Boolell (1996) ^7^ Funding source: Pfizer Inc. | N screened = NR N randomized =12 (phase I: double blind, placebo controlled four way crossover trial; phase II: double blind, randomized placebo controlled two way cross over) IG1-3/CG (both phases), n = 12 ITT analysis used for primary outcome: NR Inclusion: men 18–70 y, with penile ED of at least 6 mo, with no known organic cause by clinical examination and blood test Exclusion: pts with DM, hypertension or alcohol abuse | Age, range: 36–63 y Race: NR Co-morbidities: NR Previous ED treatment, n (%): IC papaverine 4 (30), three responders and one non responder Smoking status NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | Phase I IG: single doesesildenafil + 2 hr visual stimulation 30 min post tx (VS) CG: placebo + VS Phase II IG: sildenafil + VS CG: placebo IG (phaseI): Dose: 10, 25 or 50 mg Duration: NR Frequency: once/dose Compliance: 100% IG (phase II): Dose: 25 mg Duration: 7 d Frequency: once/d Compliance: 100% CG: Dose: NA Duration: Phase II= 7 d Frequency: phase phase II= once/d Compliance: 100% Run In period: NR Wash out period: phase I, 3 d between consecutive tx periods; 3 d between phases, phase II, at least 7 d F/u duration: 7 d | Primary outcome results: Phase I Duration of penile rigidity > 80%, mean (approximate values from figure): Base: < 4 vs. 8 vs. <12 vs. <2 min Tip: < 5 vs. <7 vs. < 8 vs. <2 min Phase II Erections of grade 3 or 4, mean: 1.6 vs. 0.5 N of erections phase I + phase II, mean (95% CI): IG vs. CG, p=0.005 6 (3.2–11.4) vs. 1.3 (0.5–2.7) Pts with improved erection, n/N (%): 10/12 (83) vs. 2/12 (16); p = 0.018 Other outcomes assessed: frequency of erection and time of dosing; pulse rate, BP, laboratory safety data Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE, n (%): phase I: 2 (16) vs. 2 (16); phase II: 6 (50) vs. 5 (41) with headache, dyspepsia, pelvic musculoskeletal pain SAE: 0 Ascertainment of outcomes assessed: RigiScan (phase I); self diary, grading erection from 1=no erection to 4=max rigidity (phase II)
Boulton (2001) ^8^ Funding source: NR | N screened = NR N randomized = 219 IG, n = 110 CG, n = 109 ITT analysis used for primary outcome: NR Inclusion: men 37 or older; with diagnosed ED, and stable type II DM (≥2 y; HbA_1c_ <11%); also in stable heterosexual relationship for longer than 6 mo Exclusion: genital anatomical deformity; major psychiatric disorder; hx of alcoholism or substance abuse; ED resulting from SCI; MI, stroke, heart failure or unstable angina within previous 6 mo; hx of hypotension; nitrate tx; type I DM; HbA_1c_ ≥11%; recurrent hypoglycemic episodes; severe disabling autonomic neuropathy; diabetes secondary to pancreatic damage; Cushing's syndrome; acromegaly | Age, mean (range): 58 (range 38–80) vs. 59 (45–72) y Race (%): White 96; Black 2 vs. 0; Asian 2; other: 1 vs. 2 Co-morbidities, %: Hypertension 40 vs. 52; Ischemic heart dx 6 v. 3; hypercholesterolemia 8 vs. 7 HbA_1c_, median, (range): 8.3 (5.1–12.1) Previous ED treatment: NR Smoking status (%): smokers 22 vs. 24 Body weigh, mean (range): 88 (60–146) kg | Concomitant medications: Insulin 32 vs. 37 Duration of ED, mean (range): 4.6 (0.4–21) vs. 3.7 (0.7–11) Underlying disease: DM Psychogenic ED: NR Physiologic ED, %: 100 Mixed ED: NR Other: duration of DM, mean (range) = 10 (1–34) y | IG: sildenafil citrate CG: placebo IG: Dose: 50 mg initially; could adjust to 25 or 100 mg Duration: 12 wk Frequency: NR Compliance: NR CG: Dose: placebo Duration: 12 wk Frequency: NR Compliance: NR Run In period: 4 wk Wash out period: NA F/u duration: 12 wk | Primary outcome results: IIEF- Q3, mean (SEM): pre: 1.8; post 3.4 (0.2) vs. 1.9 (0.2) IIEF- Q3, mean (SEM): pre: 1.5; post: 3.4 (0.2) vs. 1.8 (0.2) IIEF- EF: pre: 10.4; post: 20.4 (1.2) vs. 11.5 (1.2) Successful intercourse, %: pre 13.8; post 58.8 vs. 14.4 GEQ, %: 65 vs. 11 Other outcomes assessed: life satisfaction checklist; partner questionnaire Withdrawals/drop-outs/loss to f/u: NR WDAE, %: 0 TAE: 65 vs. 11; pts with AE= 38% vs. 6.4%; including headache 18.2 vs. 4; flushing 15 vs. 0; dyspepsia 2 vs. 0.9; abnormal vision 5 vs. 0 SAE: 0 Ascertainment of outcomes assessed: IIEF, GEQ, life satisfaction checklist
Cappelleri (2000) ^9^ ^10^ Companion Lewis (2001) Funding source: Pfizer Inc. | N screened = NR N randomized = 247 IG, n = 124 CG, n = 123 ITT analysis used for primary outcome: yes Inclusion: men 18 or older; with documented diagnosis of ED for at least 6 mo; in stable relationship with female partner for longer than 6 mo Exclusion: hx of retinitis pigmentosa; uncontrolled psychiatric disorder, hyper/hypotension or DM; serious CVD (MI, stroke or arrhythmia within previous 6 mo); evidence of alcoholism or substance abuse within previous 12 mo; current use of nitrates; nitric oxide donor | Age, mean (range): IG1 58 (range 38–77) CG 60 (range 31–81) Race (%): NR Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): Anti-inflammatory analgesic 98 (40) Antihypertensive 93 (38) Antidiabetic 49 (20) Vitamins 49 (20) Analgesic 30 (12) Diuretic 30 (12) Duration of ED, mean (range): 4 (0.4–17) y Underlying disease: Essential hypertension 83 (34) DM, Type II 49 (20) Hypercholesterolemia 37 (15) Hyperlipidemia 22 (9) Prostatic hyperplasia 30 (12) Psychogenic ED, n (%): 4 (3) vs. 6 (5) Physiologic ED, n (%): 102 (82) vs. 99 (81) Mixed ED, n (%): 36 (15) | IG: sildenafil citrate CG: placebo IG: Dose: 50 mg, with option to titrate to 100 or 25 mg Duration: 12 wk Frequency: up to once/d, 1 dose 1 hr before sexual activity Compliance: NR CG: Dose: placebo, titration as IG Duration: 12 wk Frequency: as IG Compliance: NR Run In period: 4 wk Wash out period: NA F/u duration: 12 wk | Primary outcome results: Mean response scores for questions 3 and 4 of IIEF- total, mean: pre: 9.5 vs. 9.6; post: 20 vs. 11 IIEF-EF, mean: pre: 1.7 vs. 1.6; post: 3.4 vs. 1.8 (Approximate mean values from figure): IIEF, Q3: pre: 1.8; post 3.7 vs. 2.2 IIEF, Q4: pre: 1.5; post 3.6 vs. 1.9 IIEF, Q7 (ICs): pre: 2.7; post: 3.9 vs. 2.2 GEQ-Q1, 2, %: 70 vs. 17 GEQ-Q3, least square mean: 3.5 vs. 1.8 Other outcomes assessed: EDITS; partner satisfaction; positive correlation between self-assessment and IIEF-EF at baseline and post tx Withdrawals/drop-outs/loss to f/u: 7 (6) vs. 12 (10) WDAE, n (%): 2 (1.6) vs. 0 TAE: NR; pts with AE, n (%)=52 (42) vs. 20 (16); including flushing 17 (14) vs. 1 (1); headache 14 (11) vs. 1 (1); dyspepsia 5 (4) vs. 0; abnormal vision (blue tinge to vision, ▴ sensitivity to light, eye pain, & photophobia) 3 (2) vs. 0 SAE, n (%): 3 (2) vs. 3 (2); cause NR Ascertainment of outcomes assessed: IIEF, GEQ; ED self assessment scoring system
Cavallini (2005) ^11^ Funding source: Sigma Tau (Industrie Farmaceutiche Riunite) | N screened = 139 N randomized = 110 IG1, n = 37 IG2, n = 40 CG, n = 33 ITT analysis used for primary outcome: No Inclusion: Pts complaining of ED after having bilateral nerve- sparing radical retro pubic prostatectomy 6 mo or more before the study entry with completely functional erections before the prostatectomy and had not received adjuvant or neoadjuvant tx for prostate cancer or other ED txt, having undetectable PSA levels, involvement in a heterosexual relationship for at least 6 mo before surgery Exclusion: pts with Peyronie's dx, hormonal abnormalities, Myocardial or cerebral ischemia, major surgery, tobacco/alcohol use, DM, uncompensated hyper/hyoptension | Age, mean (sd): 63 (4) vs. 61 (4) vs. 60 (5) y Race (%): NR Co-morbidities, %: compensated hypertension 53 vs. 54 vs. 62; Hypercholesteremia 53 vs. 48 vs. 55 obesity 9 vs. 7 vs. 10 Previous ED treatment: None Smoking status, %: past smokers (56 vs. 56 vs. 55) Body weight: NR | Concomitant medications: gemfibrozil, simvastatin, cilazapril, enalapril, nifedipine, quinapril, losartan, lacidipine Duration of ED (yr): NR (mean time past surgery= 1 y) Underlying disease: prostate cancer/prostatectomy Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: Sildenafil + Carnitines (acetyl- and propionyl) IG2: Sildenafil + placebo CG: placebo IG1: Dose: 100 mg sildenafil + 2 g/d each carnitine Duration: 4 mo Frequency: once/d Compliance: NR IG2: Dose: 100 mg sildenafil Duration: 4 mo Frequency: once/d Compliance: NR CG: Dose: NR Duration: 4 mo Frequency: once/d Compliance: NR Run In period: NR Wash out period: NR F/u duration: 4 mo | Primary outcome results: IIEF, mean (sd), IG1 vs. IG2 vs. CG: IIEF, EF: pre: 13 (5) vs. 11 (4); post: 27 (5) vs. 22 (7) vs. 12 (4), p < 0.05 IIEF, ICs: pre: 3 (1); post: 9 (5) vs. 5 (3) vs. 3 (0.6), p < 0.05 IIEF, OF: pre: 3 (1); post: 9 (3) vs. 6 (3) vs. 3 (0.6), p < 0.05 IIEF, SD: pre: 7 (0.7) vs. 6 (0.8); post: 6 (0.6) vs. 7(0.6) vs. 6 (0.7), p => 0.05 General sexual well-being: pre: 3 (0.7) vs. 3 (0.9); post: 8.6 (2.0) vs. 5.4 (2.7) vs. 2.8 (0.7), p < 0.05 Other outcomes assessed: Peak systolic and diastolic velocity Withdrawals/drop-outs/loss to f/u: 14 (13.5%) discontinued WDAE: None TAE, n (%): NR; AEs included headache 8 (25) vs. 9 (28) vs. 0; flushing 7 (22) vs. 8 (23) vs. 0; dizziness 3 (9) vs. 3 (9) vs. 0; nasal congestion 2 (6) vs. 2 (6) vs. 0; nausea 2 (6) vs. 2 (6) vs. 0; euphoria 2 (6) vs. 0 vs. 0; abdominal pain 0 vs. 0 vs. 1 (3) SAE: NR Ascertainment of outcomes assessed: IIEF, Doppler effect
Chen (2001) ^12^ Funding source: Pfizer | N screened = NR N randomized = 236 IG, n = 119 CG, n = 117 ITT analysis used for primary outcome: Yes Inclusion: men 26–80 y; well-documented hx of ED for at least 6 mo; in stable heterosexual relationship for at least 6 mo Exclusion: genital anatomical abnormality or SCI; other coexisting sexual disorder; elevated serum PRL level or low T level; major psychiatric disorder or hx of alcohol or substance abuse; major hematologic, renal or hepatic dx; poorly controlled DM associated with untreated proliferative retinopathy; stroke or MI in last 6 mo; hypotension or any other sign CVD; hx of retinitis pigmentosa; taking drugs known to be causally associated with ED, androgen therapy, trazodone, nitrates or nitric oxide donor compounds; receiving any tx for ED | Age, mean (range): 61 (26–80) y Race (%): Asian 100% Co-morbidities: Benign prostatic hyperplasia 40 (34) vs. 44 (38) Visual disturbance 46 (39) vs. 37 (32) Essential hypertension 30 (25) vs. 40 (34) DM 26 (22) vs. 29 (25) Arthropathies and related disorders 16 (13) vs. 14 (12) Previous ED treatment: NR Smoking status, n (%): current smoker: 27 (23) vs. 28 (24) Body weight, mean (range): 69 (46–98) kg | Concomitant medications, n (%): Antihypertensive 30 (25) vs. 43 (37) Antacid 52 (22) Antirheumatic/antigout 21 (18) Antidiabetic 38 (17) Hypnosedative/anxiolytic 26 (11) Upper respiratory tract medication 33 (14) Vitamins 30 (13) Beta-adrenoceptor blocker 23 (10) Antibacterial 23 (10) Duration of ED, mean: 4 y Underlying disease: NR Psychogenic ED, n (%): 20 (8) Physiologic ED, n (%): 193 (82)) Mixed ED, n (%): 23 (10) | IG: Sildenafil citrate CG: Placebo IG: Dose: 50 mg for first 2 wk; option to titrate to 100 mg or 25 mg Duration: 12 wk Frequency: once/d; 1 hr before sexual activity Compliance: NR CG: Dose: placebo Duration: 12 wk Frequency: as IG Compliance: NR Run In period: 4 wk Wash out period: NA F/u duration: 12 wk | Primary outcome results: IIEF, Q3, mean change from baseline: 1.9 vs. 0.7 IIEF, Q4 mean change from baseline: 2.vs. 0.9 IIEF-EF: pre: 14; post: 24 vs. 18 IIEF-ICs: pre: 5.3; post: 10 vs. 8 IIE-OF: pre: 5; post: 8 vs. 6 IIEF-SD: pre: 6; post: 7 vs. 6 IIEF-OS: pre: 4; post: 7 vs. 6 Successful intercourse, %: 62 vs. 30 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 10 (8) vs. 6 (5) WDAE, n (%): 1(<1) in IG; skin rash TAE, n (%): in at least 3 pts= 76 (64) vs. 58 (50); including: CV 34 (29) vs. 14 (12); flushing 30 (25) vs. 11 (9); palpitation 4 (3) vs. 2 (2); body as a whole 22 (19) vs. 11 (10); headache 8 (7) vs. 4 (3); abdominal pain 5 (4) vs. 0; chest pain 3 (2.5) vs. 0; respiratory system 15 (13) vs. 14 (12); nervous system 15 (13) vs. 9 (8); dizziness 9 (8) vs. 6 (5); musculoskeletal events 9 (3 (3); myalgia 3 (3) vs. 0; arthralgia 3 (3) vs. 2 (2); special senses 9 (8) vs. 2 (2); abnormal vision 3 (3) vs. 1 (0.9); skin an appendages 7 (6) vs.12 (10); fungal dermatitis 3 (3) vs. 2 (2) SAE, n (%): 4 (3) vs. 4 (3) Ascertainment of outcomes assessed: IIEF, pts filled diary
Choi (2002) ^13^ Funding source: Pfizer | N screened = 133 N randomized = 133 IG, n = 66 CG, n = 67 ITT analysis used for primary outcome: Yes Inclusion: men with ED for at least 6 mo, in a stable heterosexual relationship for 6 mo or longer Exclusion: penile anatomical abnormalities; SCI, other co-existing sexual disorders, serum PRL levels > 3x upper limit to normal, low free T (> 0% below lower limit of normal), major psychiatric disorder, hx of alcohol or substance abuse; hx of haematological, renal, hepatic dx, MI; stroke, hypotension, retinitis pigmentosa, poorly condoled or causing proliferative retinopathy DM, use of drugs associated with androgen therapy, vacuum devices or other tx for ED. | Age, mean (range): 51 (28–78) vs. 51 (32–67) y Race (%): NR Co-morbidities, n (%): Eye disorders 21 (32) vs. 14 (21) Hypertension: 13 (20) vs. 10 (15) Hyperplasia of prostate: 11 (17) vs. 12 (18); DM: 10 (15) vs. 8 (12) GI disorders: 6 (9) vs. 5 (8) Previous ED treatment: NR Smoking status, n (%): Smokers 25 (37.9) vs. 30 (44.8) Body weight, mean (range): 70 (52–102) vs. 71 (50–98) | Concomitant medications: NR Duration of ED (yr): 5 vs. 5.6 y Underlying disease: NR Psychogenic ED n (%): 21 (32) vs. 24 (36) Physiologic ED: 31 (47) vs. 26 (39) Mixed ED: 14 (21) vs. 17 (25) | IG: sildenafil CG: placebo IG: Dose: 50 mg, option for titration at 2 wks to 100, or 25 mg Duration: 8 wks Frequency: once/d Compliance (%): 100 CG: Dose: NA Duration: 8 wks Frequency: once/d Compliance (%): 97 Run In period: 4 wks Wash out period: NR F/u duration: NR | Primary outcome results: IIEF, mean score, IG vs. CG Q3: baseline=2.5; post tx: 4 vs. 3 Q4: baseline = 2; post tx: 4 vs. 2 EF domain: baseline=13; post tx: 23 vs. 15 IS: baseline= 6; post tx: 11 vs. 8 OF: baseline 5; post tx: 8 vs. 5 SD: baseline=6; post tx: 7 vs. 6 OS: baseline= 4; post tx: 7 vs. 5 GAQ, % yes: 81 vs. 28 Intercourse success, %: 62 vs. 26 Other outcomes assessed: Event logs of sexual activity Withdrawals/drop-outs/loss to f/u, n (%): 2 (3) WDAE: 0 TAE, n of events (%): 46 (70) vs. 25 (27); AE in at least 3 pts: CV=flushing 21 (32) vs. 3 (5); body as whole: 21 (32) vs. 9 (13); headache 17 (26) vs. 6 (9); Upper respiratory tract infection=nasal congestion: 5 (8) vs. 3 (4); digestive system events: 8 (12) vs. 9 (14); dyspepsia 3 (5) vs. 5 (8); special senses events: 10 (15) vs. 3 (5); abnormalities in colour vision: 4 (5) vs. 0; abnormal vision 3 (5) vs. 1 (2) SAE, n (%): 2 (3), in CG Ascertainment of outcomes assessed: IIEF, GAQ, also event logs, 12 lead ECG, standard laboratory tests
Choppin (2001) ^14^ Funding source: Roche Bioscience | N screened = NR N randomized = 24 IG1/IG2/CG, n = 24 (Latin-Square design) ITT analysis used for primary outcome: yes Inclusion: ED of continual duration ≥6 mo with no established organic cause Exclusion: NR | Age, mean (range): 44 (18–65) y Race (%): black 41.7%, white 58.3% Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: Duration of ED: at least 6 mo Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: Ro70-0004 (active alfa_1A_-adrenoceptor) + VSS IG2: sildenafil + VSS CG: placebo + VSS IG1: Dose: 5 mg (oral) Duration: NA Frequency: single dose Compliance (%): NR IG2: Dose: 50 mg (oral) Duration: NA Frequency: as IG1 Compliance (%): NR CG: Dose: placebo (oral) Duration: NA Frequency: as IG Compliance (%): NR Run In period: NR Wash out period: 7 d F/u duration: 2.5 hrs post dosing Note: last tx was repeated at 4^th^ visit | Primary outcome results: Duration of erection in 26 vs. 27 vs. 25 periods; for total of 20 pts): Base, >60% rigidity: 8.28 (3.7) vs. 22.64 (3.57) vs. 9.69 (3.71) min Tip, >60% rigidity: 5.52 (2.84) vs. 9.21 (2.75) vs. 5.33 (2.85) min Base, >80% rigidity: 0.45 (1.69) vs. 5.26 (1.63) vs. 0.67 (1.69) min Tip, >80% rigidity: 1.20 (1.20) vs. 3.18 (1.16) vs. 1.23 (1.21) min Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 4 (20) WDAE: NR TAE, n (%): any AE 2 (10) vs. 2 (9.1) vs. 1 (4.8); dizziness, hypotensive episode, GI disorder in IG1; dizziness, sedation and haematoma nose in IG2; an thrombophlebetitis in CG SAE: NR Ascertainment of outcomes assessed: RigiScan (30 min pre dose to 2.5 hrs post dose)
Christiansen (2000) ^15^ Funding source: Pfizer Ltd. | N screened = NR N randomized = 205 IG, n = 99 CG, n = 106 ITT analysis used for primary outcome: Yes Inclusion: men 18–70 y with ED of psychogenic or mixed organic/psychogenic etiology for at least 3 mo; at least 1 grade 3 or 4 erection during 4 wk before screening or positive response to IC injection test (papaverine ≤40 mg or PgE_1_ ≤20 μg) Exclusion: known vascular, neurological, endocrine or penile anatomical cause for ED; hx of major hematologic, renal or hepatic abnormality; stroke, subarachnoid haemorrhage, bleeding disorder or peptic ulceration; elevated serum PRL level; low serum T level; moderate to severe hyper/ hypotension; regular tx with nitrates, anticoagulants, major tranquillizers, estrogens or antiandrogens | Age, mean (sd): 53 (19–70) vs. 54 (21–70) y Race (%): NR Co-morbidities, %: Most frequent: Hypertension 14 Ischemic heart disease 12 Diabetes 7 Depression 5 Previous ED treatment, n (%): IC injections 86 (42) Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 4.8 (0.3–20) vs.5.3 (0.3–23) y Underlying disease: NR Psychogenic ED, %: 38 vs. 40% Physiologic ED: NR Mixed ED: 62 vs. 60 | IG: sildenafil citrate CG: placebo IG1: Dose: 10 or 25 mg, as determined during 16-wk tx phase prior to double-blind study Duration: 8 wk Frequency: up to once/d approximately 1 hr before sexual activity Compliance: NR CG: Dose: placebo Duration: 8 wk Frequency: as IG Compliance: NR Run In period: 2 wk with placebo Wash out period: NA F/u duration (both on and off treatment): 8 wk Other: 16-wk open-label treatment phase after run-in period to adjust dosage | Primary outcome results: IIEF frequency of erections when sexually stimulated, mean change in score: ▴ 1.53 vs. ▾ 0.3 Question assessing frequency of erections lasting long enough: IG1 ▴ 1.72, CG ▾ 0.13 Mean number of grade 3 or 4 erections per wk: 1.5 vs. 0.6 GAQ, % yes: 82 vs. 26 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 3 (3), all in IG1 WDAE, n (%): 4 (3), no grp designation TAE: NR, most frequent AEs in IG vs. CG/ IG in 1 y open label, n (%): headache 6 (6) vs. 2 (2)/19 (10); dyspepsia. 5 (5) vs. 3 (3)/26 (14); flushing 7 (7) vs. 1 (1)/24 (13); abdominal pain 0 vs. 4 (4)/10 (5); diarrhoea 1 (1) vs. 0; nausea 1 (1) vs. 0/4 (2); back pain 2 (1) vs. 1 (1)/11 (6); asthenia 2 (2) vs. 0/3 (2); abnormal vision including colour hue or brightness perception 2 (2) vs. 0/4 (2); conjunctivitis 2 (2) vs. 0/4 (2) SAE: 24 no grp designation, including MI in open label phase Ascertainment of outcomes assessed: IIEF, GAQ, Patient diary of grading erection (1=enlarged but not hard-4=full erection)
DeBusk, (2004) ^16^ Funding source: Pfizer Inc | N screened = 186 N randomized = 151 IG, n = 75 (ITT=70) CG, n = 76 (ITT=72) ITT analysis used for primary outcome: yes Inclusion: men 18 or older with diagnosed ED (≤ 21 on Sexual Health Inventory), confirmed, and stable CAD for at least 4 wks Exclusion: currently using prescription for and/or taking nitrates, hypotension, uncontrolled hypertension, high cardiac risk, unstable angina, hypotrophic obstructive cardiomyopathy, moderate/severe aortic stenosis, concomitant TX with drugs that inhibit P450, commercial tx for ED, previously taken sildenafil | Age, mean (range): 61 (39–82) vs. 62 (41–80) y Race (%): more than 90% White Co-morbidities: CV conditions 100% (listed in full text); Hyperlipidemia 53 (72) vs. 49 (65); pure hypercholesterolemia 38 (51) vs. 38 (50); other also listed in full text Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): medication taken by more than 50% of pts= anti-inflammatory analgesics 133 (88); hyperlipidemia 131 (87); anti-hypertensives: 113 (75); Beta Blockers: 90 (60) Duration of ED, mean: 5 y Underlying disease: NR Psychogenic ED, n (%): 5 (7) vs. 3 (4) Physiologic ED, n (%): 36 (49) vs. 34 (45) Mixed ED, n (%): 33 (45) vs. 39 (51) | IG: sildenafil CG: placebo IG: Dose: 50 mg with option to titrate to 100 or 25 mg Duration: 12 wks Frequency: up to once/d (total dose=36) Compliance (%): 80 CG: Dose: NA (titration as IG) Duration: 12 wks Frequency: up to once/d (total = 40) Compliance (%): 85 Run In period: 2 wks Wash out period: NR F/u duration: 12 wks Other: final dose, n (%)= 25 mg: 3 (4) v. 0 50 mg: 16 (22) vs. 13 (17) 100 mg: 55 (74) vs. 63 (83) | Primary outcome results: IIEF- least square mean (SE) score: Q3, baseline=2; post tx: 3.5 vs. 2.7 Q4, baseline=1.6; post tx: 3.3 vs. 2.3 GEQ, % of pts with improvement on: Erection: 59 vs. 28 Intercourse: 56 vs. 27 Intercourse success: 51 vs. 25 Other outcomes assessed: IIEF, % of max possible score (all but SD improved in IG vs. CG, p<0.02;); EDITS scores; life satisfaction checklist scores Withdrawals/drop-outs/loss to f/u: 7 (10) vs. 9 (13); including lack of efficacy in 0 vs. 4 (6) WDAE, n (%): 1 (1.4) vs. 1 (1.3) TAE, %: 47 vs. 32; AE in more than 3% of pts, n (%)=headache 6 (8) vs. 1 (1); chest pain 4 (6) vs. 2 (3); hypertension 4 (6) vs. 1 (1); flushing 6 (8) vs. 0; dyspepsia 2 (3) vs. 4 (5); leg cramps 3 (4) vs. 0; respiratory tract infection 4 (5) vs. 2 (3); nasal congestion 2 (3) vs. 0; abnormal vision 1 (1) vs. 1 (1) SAE, n (%): 1 (1.4) vs. 2 (2.6), One chest pain in IG, and urinary tract infection, severe angina pectoris in CG Ascertainment of outcomes assessed: IIEF, EDITS; GEQ, and intercourse success rate by diary; life satisfaction check list
Deveci (2004) ^17^ Funding source: NR | N screened = NR N randomized = 40 IG, n= 20 CG, n= 20 Intention to treat (ITT) analysis: NR Inclusion: NR Exclusion: presence of any contraindication for sildenafil use; hormonal disorders; performance concern; unsteady sexual partnership, past trial/use of oral sildenafil; chronic dx Data reported as IG vs. CG | Age, mean (range): 55 (25–65) y Race (%): NR Co-morbidities, n (%): DM 6 (15); hypertension 5 (12.5); benign prostatic hyperplasia 7(17.5); pts with 2 or more risk factors 4(10) Previous ED treatment: NR Smoking status, n (%): current & past smokers 9 (22.5) | Concomitant medications: NR Duration of ED: more than 3 mo Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: sildenafil sublingual CG: placebo IG: Dose: 20 mg during sexual stimulation Duration: NR Frequency: NR Compliance (%): NR CG: Dose: NR Duration: as IG Frequency: as IG Compliance (%): NR Run In period: NR Wash out period: NA F/u duration: NR | Primary outcome results: Mean ▴ in IIEF-5: 1.75 (endpoint vs. baseline p=0.02) vs. 0.6 (endpoint vs. baseline p>0.05) Overall success rates, n (%): 13 (65) vs. 3 (15) Mean onset of erection: 15.5 vs. 30 min Mean duration of erection: 40 vs. 20 min Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE, n (%): NR; headache 2 (10) vs. 1 (5); flushing 2 (10) vs. 2 (10); sweating 2 (10) vs. 0 SAE: 0 Ascertainment of outcomes assessed: pts self reports; & IIEF-5 (5 item version of IIEF)
Diamond, LE (2005) ^18^ Funding source: Palatin Technologies, Inc. | N screened = NR N randomized = 19 (cross over) IG1/ IG2/CG, n = 19 ITT analysis used for primary outcome: NR Inclusion: men 40–65 y, with diagnosed ED of at least 6 mo currently using viagra or levitra and having an adequate response to either of them Exclusion: ED caused by untreated endocrine dx, penile deformity, prostate cancer or prostatectomy, major hepatic, renal, CV, psychiatric or CNS dx, stroke, SCI | Age, mean (sd): 53 (6.7) Race (%): White 70, Black 10, Hispanic 20 Co-morbidities, %: Diabetes 10, hypertension 20, hyperlipidemia 50, obesity 10 Previous ED treatment: Viagra and levitra Smoking status: 50% (past/current) Body weight: 87 (13) kg Other: Total T level, mean: 436 (168) ng/dl | Concomitant medications: Duration of ED (yr): 5.0 (SD=5.4) Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: IIEF mean score = 21.2 (6–29) | IG1: Sildenafil + PT141 IG2: Sildenafil + placebo CG: Placebo IG1: Dose: 25 mg+7.5 mg Duration: NR Frequency: NR Compliance: NR IG2: Dose: 25 mg Duration: NR Frequency: NR Compliance: NR CG: Dose: NA Duration: NR Frequency: NR Compliance: NR Run In period: NR Wash out period: NR F/u duration: NR Other: Outcome assessments done on 3 visits 3–10 d apart and continuously monitored until 6 hrs after each dose | Primary outcome results: IG1 vs. IG2, mean (SE): Base rigidity => 60%: 112.9 (19.2) vs. 69.9 (14.3) min, p < 0.01 Base rigidity => 80%: 61 (16) vs. 40 (10) min, p=>0.05 Tip rigidity => 60%: 99.5 (16.6) vs. 40.6 (7.5) min, p < 0.001 Tip rigidity => 80%: 48.6 (12.2) vs. 20.7 (4.8) min, p < 0.05 Pts-assessed mean quality score of erection after sexual-visual stimulation (1–10) = 8.2 (0.41) vs. 6.8 (0.52), p < 0.05 Rigidity parameters improved in IG1 vs. placebo (p < 0.05) Other outcomes assessed: tumescence activity levels Withdrawals/drop-outs/loss to f/u: NR WDAE: None TAE: more and new AE observed with combination tx; flushing one also had nausea 4 (21%) vs. 0 vs. 0; headaches 0 vs. 1 vs. 1 SAE: 0 Ascertainment of outcomes assessed: RigiScan and questionnaire
Dinsmore, W (1999) ^19^ Funding source: NR | N screened = 127 N randomized = 111 IG, n = 57 CG1, n = 54 CG2, n= 109 (separate parallel study, no treatment, age matched, healthy subjects, single-visit data not included in this table) ITT analysis used for primary outcome: Yes Inclusion: men older than 18 with clinical diagnosis of ED of at least 6 mo, participated in a stable, heterosexual relationship for at least 6 mo and to forego self-injection programs Exclusion: advanced vascular, neurological, endocrine, or anatomic causes for ED, major hematologic, renal, or hepatic abnormalities, regular use of nitrates, hx of stroke in the past 6 mo. or currently active peptic ulceration, tx with any experimented drugs in the 3 mo. preceding the study | Age, mean (range): 56 (30–78) vs. 55 (29–89) y Race (%): NR Co-morbidities, %: hypertension IG 9 vs. 11; DM 7 vs. 7; ischemic heart disease 1 vs. 1 Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): NR Underlying disease: NR Psychogenic ED (%): 40 vs. 39 (CG1) Physiologic ED (%): 21 vs. 20 Mixed ED (%): 39 vs. 37 | IG: sildenafil (self-administered) CG: placebo CG2: no treatment IG: Dose: 25 mg (option to ▴ to 50 mg, max. 100 mg) Duration: 12 wks Frequency: 1-hr pre sexual activity but not > once daily Compliance: 87 % CG: Dose: NA (option to ▴ to 50 mg, max. 100 mg) Duration: 12 wks Frequency: 1-hr pre sexual activity but not > once daily Compliance (%): NR Run In period: 2–4 wks Wash out period: NR F/u duration (both on and off treatment): 12 wks + 2 wks = 14 wks | Primary outcome results: IIEF-Q1–15, range: pre (except Q11, and 12) </= 2.52; post tx range 2.77–3.92 vs. 1.37–3.10, sign ▴ (p < 0.01) GEQ, % improved: 81% vs. 18% (p<0.0001) Grade 3 or 4 erection/mo, mean (event log): 6.9 vs. 2.4 (p<0.0001) Successful sexual intercourse attempts: 73% vs. vs. 30% (p<0.0001) Other outcomes assessed: all IIEF items Withdrawals/drop-outs/loss to f/u, n (%): 14 (13) including 3 in IG, and 11 in CG discontinued tx due to lack of efficacy WDAE: 0 TAE, n (%): 18 (30) vs. 3 (5.5) headache 7(12%) vs.1 0; flushing 5 (9) vs. 2 (4); dyspepsia 4(7) vs.1 (2); abnormal vision 2 (4) vs. 0 SAE, n: nr Ascertainment of outcomes assessed: 15-item IIEF; GEQ; event log with of erection using a 5-point scale grading system (0 =no sexual activity; 1=almost never; 5=almost always) (added”)
Dunzendorfer (2002) ^20^ Funding source: NR | N screened = NR N randomized = 77 (cross over) IG1, n = 44 IG2, n = 33 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: pts with ED, and low to non-response to 5 PDE inhibitors; with complaint of prostate disease Exclusion: NR | Age, mean (range): 62 (34–77) y Race: NR Co-morbidities: NR Previous ED treatment: 100% with PDE-5 inhibitors; 4 wks screening drug program for low responders to (n=58), 3 hrs before sildenafil 100 mg intake (dose/ sexual activity): Midodrine 25 mg; Testosterone 250 mg/wk; Ginseng 900 mg; Yohimbine 15 mg; Akatinol 10 mg; Apomorphine4 mg; Hydergin-S 8 mg; Prazosi 4 mg; DHE 5 mg Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): DM 4 (5); hypertension 17 (22); prostate dx 77 (100); mixed vasculogenic 77 (100) Psychogenic ED, n (%): NR Physiologic ED, n (%): 100% Mixed ED, n (%): NR | IG1: A: Sildenafil/ B: Sildenafil + Dihydro-ergotamine (DHE) IG2: A: Sildenafil + DHE/ B: Sildenafil IG1: Dose: slidenafil 50 mg, titrated to 100 mg; DHE 5 mg Duration: NR Frequency: twice / wk Compliance: NR IG2: Dose: 50 mg (titration as IG1)+ 5 mg DHE Duration: NR Frequency: as IG1 Compliance: NR Run In period: 4 wks (see previous ED tx) Wash out period: 4 wks F/u duration: NR Other: Pts received tx A (IG1) or B (IG2) followed by a wash out period and then crossed over to B (IG1) or A (IG2) respectively | Primary outcome results: Mean IIEF Q3, 4, 5 and 6, range of mean scores per question, (SD range): Baseline (run in) = 1.1–1.8 (0.2–0.4) 50 mg sildenafil alone = 1.1–2.1 (0.2–0.4) 100 mg sildenafil =1.5–2.1 (0.3–0.4) DHE alone = 1.3–2.2 (SD range 0.2–0.5) Combination 50 mg sildenafil + DHE =2.9–3.2 (0.5–0.7) 100 mg sildenafil + DHE = 3.5–3.8 (.6–0.8) Other outcomes assessed: NO-cAMP (N1 oxide cyclic adenosine monophosphate), and cGMP (cyclic guanosine monophosphate) levels in corpora cavernosa; urodynamic profile Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE: NR TAE: NR (authors claim that combination tx reduced AE) SAE: NR Ascertainment of outcomes assessed: IIEF, lab measures
Eardley (1999) ^21^ Funding source: NR | N screened = NR N randomized = 16 (cross over) IG/CG = 16 ITT analysis used for primary outcome: No Inclusion: men 18 or older, with ED of no known organic cause Exclusion: Hx of DM, untreated hypogonadism; tx with nitrates, antidepressants or tranquilizers. Concomitant sign.arterial disease; other tx for ED less than 2 wks prior to start of study | Age, mean (range): 35–68 (57) y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 1.9 (0.25 – 8) y Underlying disease: NR Psychogenic ED: NR Physiologic ED: 0 Mixed ED: NR | IG: sildenafil CG: Placebo IG: Dose: 100 mg Duration: 2–5 hrs Frequency: twice Compliance (%): 100% CG: Dose: NA Duration: 2–5 hrs Frequency: twice Compliance (%): 100% Run In period: 2 wks Wash out period: 7 d F/u duration: f/u assessments at 2 and 4 hrs post dosing | Primary outcome results: Pts with grade 3 or 4 erection, n (%): IG only 13 (81.25) Duration of erection 2 hrs post dosing, mean: RigiScan, erections with > 60% rigidity at base: At 2 hrs post dosing: IG 2.5 min (responders = 4.1 min) At 4 hrs post dosing: IG responders = 2.2 min, for IG1 = 1.4 min Pts rated erection, grade 3 or 4: responders: At 2 hrs post dosing: 23.8 minutes At 4 hrs post dosing: IG responders 17.2 min Other outcomes assessed: None Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: 0 SAE: 0 Ascertainment of outcomes assessed: RigiScan, self-rating scale
Eardley (2001) ^22^ Funding source: Pfizer Inc. | N screened = 47 N randomized = 44 (crossover design) IG/CG, n = 44 ITT analysis used for primary outcome: Yes (n=40) Inclusion: men18–70 y; clinical diagnosis of ED of no established organic cause for longer than 6 mo; in stable relationship with female partner; have residual ED (at least one grade 3 or 4 erection) or positive response to papaverine or PgE_1_ injection within 4 wk of study entry Exclusion: having 2 successive penetrative sexual intercourse acts per wk; hx of alcohol misuse; regular tx with nitrates, anticoagulants or acetylsalicylic acid within 2 wk; tx with antidepressants or major tranquillizers for psychoses or related conditions; continued use of other ED tx | Age, mean (range): grp: 53 (33–69) y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 3 (0.5–10) y Underlying disease: NR Psychogenic ED: 100% Physiologic ED: 0 Mixed ED: NR | IG1: sildenafil CG: placebo IG1: Dose: 25 mg with option to titrate to 50 mg and then 75 mg if necessary Duration: median 29 d (two 28 d tx periods) Frequency: 1 dose 30–60 min before sexual activity; max. 1/d Compliance: 91% took at least one dose CG: Dose: placebo (titration as IG) Duration: as IG Frequency: as IG Compliance: as IG Run In period: None Wash out period: None F/u duration: 10 wk (2 wks post last tx period) Other: 24 pts received sildenafil first, and 20 received placebo first; each period lasted for 28 d | Primary outcome results: Geometric mean number of grade 3 or 4 erections per wk: 4.2 vs. 1.4 Erection of grade 3 or 4/ doses: I94 vs. 68 Intercourse success/ dose, %: 62vs. 12 GEQ-Q1 (improved erection), % yes: 34 (94) vs. 9 (25) GEQ-Q2 (ease of use), %: 33 (94) vs. 13 (37) Other outcomes assessed: partners' assessment of quality of erections Withdrawals/drop-outs/loss to f/u: 5 (11) WDAE, n (%): 0 vs. 1 (<1) TAE, n (%): all reporting AE 23 (53) vs. 14 (33); tx related AE: headache 11 (26) vs. 0; flushing 4 (9) vs. 0; dyspepsia 3 (7) vs. 1 (2); arthralgia 3 (7) vs. 2 (5) SAE, n (%): 0 vs. 1 (<1) MI in second period Ascertainment of outcomes assessed: daily log of erection (grading system 1–4), and intercourse satisfaction
Eardley (2002) ^23^ Study a Funding source: NR | N screened = 17 N randomized = 17 (two-way crossover study) IG, CG, n = 17 ITT analysis used for primary outcome: No Inclusion: age 35–70 y, clinical diagnosis ED, no organic cause for at least 6 mo Exclusion: hx of serious medical conditions (DM, untreated hypogonadism, sign arterial dx, migraine headaches, alcohol or substance abuse. Current tx with nitrates, antidepressants, tranquilizers or anticoagulants. Other therapies for ED (e.g. E_1_ IC) discontinued 2 wks prior to start of study | Age, mean (range): 52yrs (37–70) Race (%): NR Co-morbidities: NR Previous ED treatment: 4 received prostaglandin, 2 yohimbine, 1 an investigational drug Smoking status: NR Body Weight: NR Other: other conditions, n (%); vasectomy 3 (17.6%), 1 unilateral orchidectomy, prostatitis 1 (5.8%), caricosities 1(5.8%) | Concomitant medications: NR Duration of ED: 3.1 y (0.5–19) Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: sildenafil + 60 min visual sexual stimulation (VSS) CG: placebo + 60 min visual sexual stimulation IG: Dose: 50 mg Duration: NR Frequency: once Compliance (%): 100% CG: Dose: NA Duration: NR Frequency: once Compliance (%): 100% Run In period: NR Wash out period: 7 d F/u duration: NR | Primary outcome results: Proportion of responders with rigidity > 60%, n (%): 14 (82) vs. 9 (53) Pts with grade 3 or 4 erection: 12 (71) vs. 6 (35) Time to onset of erections (median): 27 min (range 12–70) vs. 50 min The onset of erections occurred only after VSS; 8 (47%) responded to both active and placebo tx Other outcomes assessed: none Withdrawals/drop-outs/loss to f/u, n (%): 1 WDAE: 0 TAE: NR SAE: NR Ascertainment of outcomes assessed: RigiScan; physical exam, patient report; standard laboratory tests
Eardley (2002) ^23^ Study b Funding source: NR | N screened = 16 N randomized = 16 (two-way crossover) IG/ CG, n = 16 ITT analysis used for primary outcome: No Inclusion: men 35–70 yrs, clinical diagnosis ED, no organic cause for at least 6 mo Exclusion: hx of serious medical conditions (DM, untreated hypogonadism, sign arterial dx, migraine headaches, alcohol or substance abuse. Current tx with nitrates, antidepressants, tranquilizers or anticoagulants; other therapies for ED (IC injections) discontinued 2 wks prior to start of study. | Age, mean (range): 57 (35–68) y Race (%): NR Co-morbidities: NR Previous ED treatment: none Smoking status: NR Body weight NR Other: pts conditions, n (%) vasectomy 7 (43.8), undescended right testicle 1 (6.3), prostatitis, redundant prepuce 1 (6.3), scrotal cyst 1 (6.3), hyperplasia of the prostate 1 (6.3) | Concomitant medications: NR Duration of ED (mean yrs, range): 1.9 (3–8.0) y Underlying disease (diagnosis) (N or % of diseased/ grp): NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: sildenafil+ 60 min visual sexual stimulation (VSS) CG: placebo + 60 min VSS IG1: Dose: 100 mg Duration: NR Frequency: twice Compliance (%): 100% CG: Dose: NA Duration: NR Frequency: twice Compliance (%): 100% Run In period: NR Wash out period: NR F/u duration: four assessment at 3 hrs and 5 hrs Other: pts received 4 tx (2 active and 2 placebo) | Primary outcome results: Proportion of responders with rigidity > 60%, n (%): 3 hrs post VSS: 12 (75) vs. 5 (31) 5 hrs post VSS: 13 (81) vs. 5 (31) Duration of erection, mean (SE): 3 hrs post VSS: 19.4 (4.1) vs. 3.9 (2.1) min 5 hrs post VSS: 17.2 (4.0) vs. 3.6 (2.0) Other outcomes assessed: none Withdrawals/drop-outs/loss to f/u, n (%): 1 (6.3) WDAE: 0 TAE: NR SAE: NR Ascertainment of outcomes assessed: RigiScan; physical exam patient report, standard laboratory tests
Eardley (2005) ^24^ Funding source: Lilly ICOS LLC | N screened = 411 N randomized = 367 IG1, n = 183 (first period) IG2, n = 184 (first period) CG, n = NA ITT analysis used for primary outcome: Yes Inclusion: Pts aged => 18 yr with documented ED of any aetiology and severity, in a steady relationship with the same female partner naïve to treatment for ED with drugs inhibiting PDE5 Exclusion: Pts with endocrine dx, premature ejaculation, prostatectomy, pelvic surgery, penile deformity, sign renal or hepatic dx, CHF, Within 6 mo, MI, coronary artery bypass surgery, sudden cardiac arrest, SBP (< 90 - > 170 mmHg) or diastolic (< 50 - > 100 mmHg), malignant hypertension, retinitis pigmentosa, current tx with nitrates, cancer chemotherapy, HIV infection, substance/drug abuse in last 6 mo | Age, mean (sd): 54 (12) y Race (%): Caucasian 92, Black 4, Asian 3, other 1.3 Co-morbidities, (%): Hyperlipidemia 11, coronary artery dx 6.5, hypertension 26.4, DM 9.5, depression 4 Previous ED treatment: NR Smoking status, (%): current = 24 Body weight: NR Other: current alcohol use (65%) | Concomitant medications: no other ED treatments Duration of ED: NR (pts with 1 y or more ED =74%) Underlying disease: NR Psychogenic ED: 12% Physiologic ED: 28% Mixed ED: 60% Other: ED defined as consistent change in the quality of erection that adversely affects subject's satisfaction with sexual intercourse Other: Mean IIEF (EF): 14 (6); Severity of ED: severe (IIEF1–10): 31%, moderate (IIEF 11–16): 30%, mild (IIEF 17–30): 39% | IG1: Sildenafil IG2: Tadalafil IG1: Sildenafil Dose: 25–100 mg Duration: 12 wks Frequency: NR Compliance: NR IG2: Tadalafil Dose: 10–20 mg Duration: 12 wks Frequency: NR Compliance: NR Run In period: 4 wks Wash out period: 7–10 d F/u duration: before and after crossover 24 wks (2 periods of 12 wks) Other: Dose was titrated up and down between 25–100 for Sildenafil and 10–20 mg for Tadalafil | Primary outcome results: Mean least squares change from baseline for IIEF domains and 95% CI (IG2 vs. IG1): EF: 0.5 (-0.07, 1.1) OF: 0.3 (0.02, 0.5) SD: 0.2 (0.02, 0.6) Intercourse satisfaction: 0.17 (-0.1, 0.42) Mean change in IIEF questions: erection firmness, intercourse satisfaction and enjoyment, desire level, OS, erection confidence: tadalafil > sildenafil OS: 0.3 (0.02, 0.5) SEP, mean change from baseline: SEP-Q2: 36 vs. 39 SEP-Q3: 53 vs. 58 Other outcomes assessed: mean scores of IIEF, drug preference Withdrawals/drop-outs/loss to f/u: IG1 (1^st^) and IG2 (2^nd^): n=42 IG1 (2^nd^) and IG2 (1^st^): n=39 WDAE: IG1 (1^st^) and IG2 (2^nd^): n=4 IG1 (2^nd^) and IG2 (1^st^): n=7 TAE, n (%): pts with 1 or more AE=125 (34) vs. 128 (35) SAE, n: 4 (2) vs.5 (3) Ascertainment of outcomes assessed: Questionnaires
Fava (2006) ^25^ Funding source: Pfizer Inc. (conflict of interest for authors; paid by Pfizer, and other sources) | N screened = NR N randomized = 142 IG1, n = 71 CG, n = 71 ITT analysis used for primary outcome: NR Inclusion: men 18 or older with ED diagnosed by Sexual Health Inventory for Men (SHIM) score of 21 or less, and diagnosed major depressive disorder (MDD) according to DSM-IV criteria in remission in stable relationship Exclusion: symptomatic for depression or anxiety despite tx; pts requiring tx with antipsychotics, mood stabilizers, other nonserotonergic antidepressant agents or lithium; use of nitrates or any commercially available for ED | Age, mean (range): 51 (27–74) y Race, %: White 86 vs. 92%; Black 6 vs. 3%; Asian 3 vs. 0%; other 6% in both grps Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight, mean (range): 92 (57–191) vs. 92 (60–138) kg | Concomitant medications, n (%): antidepressant therapy, selective SRI 133 (94); serotonin-norepinephrine reuptake inhibitor 10 (7); other antidepressant drugs 10 (7) Duration of ED, mean (range): 2.7 (0.1–14.2) vs. 2.2 (0.2–11.6) y Underlying disease, n (%): depression Psychogenic ED, n (%): 100% Physiologic ED: NA Mixed ED: NR | IG: Sildenafil CG: Placebo IG: Dose: 50 mg titrated to up to 100 or down to 25 mg based on efficacy and tolerance Duration: 6 wks Frequency: NR Compliance: CG: Dose: NA Duration: 6 wks Frequency: NR Compliance: Run In period: Wash out period: F/u duration: Other: mean dose taken/ mo= 13.6 vs. 11; 65% on 100 mg 34% on 50 mg and 1% on 25 mg sildenafil at end of study | Primary outcome results: IIEF mean score: Q3: baseline 2.4; post tx 3.9 vs. 3.1, p=0.003 Q4: baseline 2.1; post tx 3.7 vs. 2.8, P<0.001 GEQ- Q1, % improved: 70.6 vs. 28.8 GEQ-Q2, % improved: 72.1 vs. 27.7 GEQ-Q3, mean (SE) scale of 1–5: 2.5 (0.2) vs. 1.3 (0.2) Event log, mean (SE) N of events/ wk: N of sexual intercourse attempts: 2.6 (0.2) vs. 1.9 (0.2) N of successful attempts: 1.9 (0.2) vs. 0.6 (0.2) Successful attempts/ wk, % (95% CI): 71 (60 to 80) vs. 31 (22 to 43) Other outcomes assessed: All EDITS questions indicated tx success with sildenafil Withdrawals/drop-outs/loss to f/u, n (%): 9 (12.7) vs. 4 (5.6) WDAE: NR TAE, n (%): NR; all included headache 6 (9) in all; dyspepsia 6 (9) vs. 1 (1); anxiety 4 (6) vs. 3 (4); abnormal/ blurry vision 2 (3) vs. 0 SAE, n (%): 0 Ascertainment of outcomes assessed: IIEF, EDITS, GEQ
Fowler (2004) ^26^ Funding source: Pfizer Inc. | N screened = 256 N randomized = 218 IG, n = 104/ (102, 98% completed) CG, n = 113/ (n= 88, 78% completed) Intention to treat (ITT) analysis: yes Inclusion: men 18 yr or older, ED of at least 6 mo; diagnosis of multiple sclerosis (MS) of at least 1 yr (criteria not defined/ type of MS not defined), with residual disability level of 2–6 (ambulatory) based on Kurtzke Extended Disability Status Scale (EDSS) Exclusion: penile deformities; major haematological, renal or hepatic abnormalities, coexistence /sexual dx as primary cause; uncontrolled psychiatric condition; cardiovascular disorder; unknown hx of retinitis pigmentosa; use of nitrates, or corticosteroids (last 2 mo); nitric oxide donors | Age, mean: 46 y Race (%): NR Co-morbidities: 100% MS (mean duration 10.4 y) Previous ED treatment: NR Smoking status: NR Note: data reported for IG vs. CG | Concomitant medications: (used by > 10% of pts) analgesics; antibacterial; antidepressants; antihypertensive (> in CG); corticosteroids (> in IG); drugs affecting immune response, muscle relaxants; rheumatic diseases medication; vitamins Duration of ED: mean (range) 5.2 (0.7–23.1) vs. 6.1 (0.9–29) yr Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: Sildenafil CG: placebo IG: Dose: 50 mg (32%); titrated up to 100 (64%), or down to 25 mg (4%) based on patient response & tolerability Duration: 12 wks Frequency: max once / d, 1 hr before sexual activity Compliance (%): NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance (%): NR Run In period: 4 wks Wash out period: NA F/u duration: 12 wks Note: this trial was followed by an open label period of 24–48 wks (n=206) & included those with non tx related AE; (50 mg sildenafil) | Primary outcome results: IIEF-Q1 (improvement in erection), % of pts: 90% vs. 24%, p<0.0001 Q2 (satisfactory erection for intercourse), % of pts: 92% of responders to Q1 Q3/Q4: IG better than CG, p<0.0001 Q9/ Q10: IG better than CG, p< 0.0001 Q11/ Q12: IG better than CG, p=0.0002 GEQ3, mean score: 4 vs. 2 Other outcomes: quality of life, IG did better in 5/8 variables than CG, (sexual life 86% of pts vs. 22%) Withdrawals/drop-outs/loss to f/u, n (%): 2 (2) vs. 25 (22) WDAE: 0 vs. 1% TAE (%): AE in more than 3% of pts in IG vs. CG/IG open label=66.3 vs. 43.4/73; headache 27 vs. 7/23; flushing 13 vs. 2/16; weakness 6 vs. 1/4; MS relapse 7 vs. 2/10; rhinitis 6 vs. 1/7; chromatopsia 4 vs. 0/4; dyspepsia 6 vs. 0/6 SAE, n (%): 3 (3) vs. 3 (3), urinary tract infection, worsening, & exacerbations of MS in IG; weakness, bone disorder, MI in CG Ascertainment of outcomes assessed: IIEF; GEQ, quality of life questionnaire
Gentile (2004) ^27^ Funding source: Sigma-Tau, Italy | N screened = NR N randomized = 40 IG, n = 20 CG, n = 20 ITT analysis used for primary outcome: N Inclusion: men 18 or older, with ED, in a stable relationship of more than 6 mo; type 1 DM of at least 5 y or type 2 DM of at least 2 y (defined by National Diabetes Data Group), medical management of DM for 6 mo., HbA1C levels < 11% Exclusion: genital anatomical deformities, a primary dx of a sexual disorder other than ED, a poorly controlled major psychiatric disorder, a recent hx of major haematological, renal or hepatic abnormalities, MI, stroke, heart failure, unstable angina or hypotension, or tx with nitrates, HbA1C levels ≥ 11% (Complete list in full text article) | Age, mean (range): 64 (45–81) y Race (%): Caucasian 100 % Co-morbidities, %: hypertension 31 vs. 34; peripheral vascular dx 4 vs. 3; other 3 vs. 2 HbA1C level, % (range): 8.6 (5.7–11.3) vs. 8.4 (5.6–10.9) Previous ED treatment: Viagra monotherapy in all Smoking status: smoker 32 vs. 29 Body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 5.7 (0.7–22) vs. 5.3 (0.6–19.5) y Underlying disease, %: DM type 1= 18 vs. 16; DM type 2= 82 vs. 84 Organic ED, (%): 65 vs. 66 Mixed ED, %: 35 vs. 34 | IG: propionyl-L carnitine (PLC) + sildenafil CG: placebo PLC + sildenafil IG: Dose: 2 g PLC+ 50 mg sildenafil Duration: 24 wks Frequency: once/d + twice/wk Compliance: NR CG: Dose: 2 g (placebo) + 50 mg sildenafil Duration: 24 wks Frequency: as IG Compliance: NR Run In period: 4 wks Wash out period: NR F/u duration: 24 wks | Primary outcome results: IIEF-Q3, mean (sd): 4.3 (0.6) vs. 3 (0.7), p<0.01 IIEF-Q4, mean (sd): 3.9 (1) vs. 2.7(0.9), p<0.01 GEQ, (% yes): 68 vs. 23, p<0.01 Successful attempts of intercourse (Event logs), %: ▴ from 11% to 34% vs. ▴ 10% to 76%, p<0.01 Other outcomes assessed: vascular evaluations [e.g. cavernosal artery; PSV, resistance index (RI)] Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: gastric pain 2 vs. 0 SAE: 0 Ascertainment of outcomes assessed: IIEF; GEQ
Gingell (2004) ^28^ Funding source: Pfizer | N screened = 17 N randomized = 16 (four way crossover trial) IG/ CG, n = 16 ITT analysis used for primary outcome: yes (n=16) Inclusion: sildenafil naïve men 18 to 70 y and had been diagnosed with ED of no known organic cause for longer than 6 mo Exclusion: Men who had not experienced at least one erection of sufficient rigidity for penetrative intercourse in the previous 4 wks, or failed to give positive response to IC prostaglandin or papaverine at screening; hx of DM, untreated hypogonadism; sign arterial, renal or hepatic dx or used antidepressants, tranquilizers, nitrates, IC injections or any other tx for ED in 2 wks. | Age, mean (range): 55 (36–68) y Race, n (%): White 16 (94) Co-morbidities: NR Previous ED treatment: None within last 2 wks. Smoking status: NR Body weight, mean (sd): 83 (10) kg | Concomitant medications: None Duration of ED: ≥ 6 mo Underlying disease: None Psychogenic ED: None Physiologic ED: None Mixed ED: None | IG: Sildrnafil (mix of both given at diff time periods) CG: Placebo IG: Dose: 100 mg Duration: three 14 hr inpatient stay in 4 wks Frequency: once/ session (at one of either 12, 8, or 1 hr prior to VSS) Compliance: 100% CG: Dose: 3 tablets Duration: one14 hr inpatient stay Frequency: as IG Compliance: 100% Run In period: NR Wash out period: 7 d F/u duration: 4 wks Other: pts were randomized into sequence grps (I–IV) and sildenafil or placebo administered test periods (A–D) | Primary outcome results: Duration of erections of ≥60% rigidity, mean for IG at 1, 8, 12 hr prior to VSS vs. CG: 26, 11, 8 vs. 3.4 min Duration of grade 3 or 4 erection, (hard enough, completely hard) at 1, 8, 12 hr: 33, 23, 16 vs. 7 min (75% reported grade 3 or 4 after 2 hrs) Other outcomes assessed: Proportion of sildenafil responders 1,8, 12 hrs, %: 69, 60, 31; 82% after 8 hrs, and 54% after 12 hrs Withdrawals/drop-outs/loss to f/u: 1 pts excluded (use of IC injection during trial) WDAE: None TAE: NR; most common, AEs at 1, 8, and 12 hrs pre VSS 27 vs. 1; AEs included headaches 12 vs. 0; flushing 9 vs. 0; diarrhea 1 vs. 0; dry mouth 1 vs. 0; GI disorder 1 vs. 1; respiratory tract infection 1 vs. 0; visual disturbances (chromatopsia) 2 vs. 0 Most common headache: 12 Facial Flushing: 9 CG n: Gastro 1 SAE: None Ascertainment of outcomes assessed: RigiScan; self-assessed duration of grade 3 or grade 4 erections:
Glina (2001) ^29^ Companion Glina (2002) ^30^ Funding source: Pfizer | N screened = NR N randomized = 245 (Parallel grp) IG, n = 124 CG, n = 121 ITT analysis used for primary outcome: Yes Inclusion: Brazilian and Mexican men 18 or older with ED of broad-spectrum etiology ≥6 mo in a stable, heterosexual relationship for a duration of ≥ 6 mo. Exclusion: genital anatomical deformities; ED secondary to SCI, primary diagnosis of other sexual disorders; uncontrolled DM; hx of stroke, MI or sign. CV disease within previous 6 mo, hypotension or hypertension; alcoholism or substance abuse; receiving nitrates or nitric oxide | Age, mean (range): 58 (28– 85) vs. 55 (27– 84) Race, n (%): Hispanic: 60 (48.4) vs. 57 (47.1); White 60 (48.4) vs. 58 (47.9); Other: 4 (3.2) vs. 6 (5) Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: antihypertensives, insulin and antidiabetics, beta-adrenoreceptor blockers, hypnotics, sedatives, anxiolytics, anti-inflammatory analgesics, diuretics, hyperlipidemia tx Duration of ED, mean (range): 3.7 (0.5 – 25.6) vs. 3.4 (0.5 – 21.7) y Underlying disease (diagnosis); n (%): Hypertension 36 (29) vs. 29 (24); DM 30 (24) vs. 22 (18); Prostatic hyperplasia 6 (5) vs. 8 (7); Visual disturbance 5 (4) vs. 7 (5.8) Psychogenic ED; n (%): 25 (20.2) vs. 18 (14.9) Physiologic ED: Organic: 51 (41.2) vs. 50 (41.3) Mixed ED; n (%): 48 (38.7) vs. 53 (43.8) | IG: Sildenafil citrate CG: Placebo IG: Dose: 25, 50 or 100mg Duration: 12 wks Frequency: once daily 1 hr before sexual activity Compliance (%): 91 CG: Dose: NA Duration: 12 wks Frequency: once daily 1 hr before sexual activity Compliance (%): 89 Run In period: 4 wks Wash out period: NA F/u duration: 12 wks | Primary outcome results: IIEF, mean (SE): Q3 (penetration): 3.93 (0.15) vs.2.56 (0.16) Q4 (maintained erections after penetration): 3.83 (0.15) vs. 2.33 (0.15) GEQ, % improved erection: 81% vs. 36% GEQ, % with successful intercourse: 71% vs. 32% % maximal domain score from graph ^30^ : baseline (pre); post intervention IG vs. CG EF: pre 40; post 75 vs. 50 OF: pre 59; post 84 vs. 68 SD: pre 70; post 79 vs. 70 IS: pre 44; post 69 vs. 55 OS: pre 40; post 76 vs. 50 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 15 (12.1) vs. 16 (13.2) WDAE, n (%): 1 (0.8) vs. 0 TAE (%): 35% vs. 20%, flushing 11(8.9), vs. 0; headache 15 (12) vs. 6 (5); dyspepsia 9 (7) vs. 0; rash 5(4) vs. 0; dizziness 4(3) vs. 1(0.8); abnormal vision 4 (3.2) vs. 1 (0.8); rhinitis 3(2.4) vs. 1(0.8) SAE: 1 (<1) vs. 5 (4), no reasons provided Ascertainment of outcomes assessed: Q3 and Q4 and GEQ ^29^ 15 item IIEF questionnaire, and event log
Goldstein (1998) ^31^ Companion ^32^ Study a Funding source: Pfizer | N screened = NR N randomized = 532 (dose response) IG, n = 316 (completers: IG1, n = 96; IG2, n = 105; IG3, n= 101) CG, n = 216 (completers =199) ITT analysis used for primary outcome: yes Inclusion: men in stable relationship 6 mo or longer, with ED confirmed by clinical exam and IC injection of vasoactive drug (31% of men), normal NPT, penile duplex ultrasonography, and endocrine testing Exclusion: penile deformities, another sexual disorder; SCI, major psychiatric dx; poorly controlled DM; peptic ulcer dx, hx or alcohol or substance abuse; hematologic, renal or hepatic abnormalities, recent stroke or MI in last 6 mo; nitrate therapy | Age, mean (range): 58 (24–87) vs. 57 (20–79) y Race: NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean: 3.2 y Underlying disease (% of pts): hypertension 30 vs. 26; ischemic heart dx 8; hyperlipidemia 19 vs. 16; hx or radical prostatectomy 12 vs. 10; DM 13 vs. 15 Psychogenic ED (%): 9 vs. 10 Physiologic ED (%): 78 vs. 77 Mixed ED (%): 13 (both grps) | IG1/3: Sildenafil- oral CG: placebo- oral IG1-3: Dose: 25 mg (IG1), 50 mg (IG2), 100 mg (IG3) Duration: 24 wk Frequency: once/d (one hr prior to sexual activity) Compliance: 97% CG: Dose: NA Duration: 24 wk Frequency: as IG Compliance: 99% Run In period: NR Wash out period: NR F/u duration: 24 wks | Primary outcome results: IIEF, Q3/ Q4 (similar values for both), mean (sd) score: Baseline: IG=CG 2 (0.2); Post tx: 3–4 (0.2) vs. 2 (0.2) IIEF-EF: increase in score with dose escalation, IG vs. CG p<0.001 Grade 3 or 4 erection, (%): 72, 80, 85 vs. 50% (80% of grade 3 and 94% of grade 4 erections resulted in intercourse; positive dose response) Improved erection (% of pts): 56, 77, 84 vs. 25, p< 0.001 Other outcomes assessed: IIEF, Q6, 7, 8, 13 and 14 (> in IG); SD (no change) Withdrawals/drop-outs/loss to f/u, n (%): IG=31 (10) [15 (15), 8 (7), 8 (7)] vs. CG =36 (17) WDAE: 4 (1) vs. 1 (<1) TAE, n (%): in 5% of pts or more IG 15 (15)/ 8 (7)/ 8 (7) vs. CG 36 (17); AE included headache 14–32 (14–30) vs. 14 (6); flushing 13–29 (13–27) vs. 3 (1); dyspepsia 3–17 (3–16) vs. 3 (1); rhinitis 1–12 (1–11) vs. 4 (2); visual disturbance 2–10 (2–9) vs. 1 (<1) SAE: NR Ascertainment of outcomes assessed: IIEF; ED validated questionnaire; self report event log (grading system)
Goldstein (1998) ^31^ Study b Funding source: Pfizer | N screened = NR N randomized = 329; (dose escalation + open label extension) IG, n = 163 CG, n = 166 ITT analysis used for primary outcome: yes Inclusion: men in stable relationship 6 mo or longer, with ED confirmed by clinical exam and IC injection of vasoactive drug (31% of men), normal NPT, penile duplex ultrasonography, and endocrine testing Exclusion: penile deformities, another sexual disorder; SCI, major psychiatric dx; poorly controlled DM; peptic ulcer dx, hx or alcohol or substance abuse; hematologic, renal or hepatic abnormalities, recent stroke or MI in last 6 mo; nitrate therapy | Age, mean (range): 60 (26–79) vs. 59 (31–81) y Race: NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean: 5 y Underlying disease (% of pts): hypertension 24 vs. 28; ischemic heart dx 15 vs. 8; hyperlipidemia 15 vs. 14; hx or radical prostatectomy 9 vs. 11; DM 8 vs. 11 Psychogenic ED, n (%): 14 vs. 16 Physiologic ED, n (%): 55 vs. 63) Mixed ED, n (%): 31 vs. 22 | IG: Sildenafil -oral CG: placebo- oral IG: Dose: 50 mg (titrated at each f/u visit to double or 50% less based on the therapeutic response and AE) Duration: 12 wk Frequency: once/ d (one hr before sexual activity) Compliance: 94 CG: Dose: NA Duration: 12 wks Frequency: as IG Compliance: 92 Run In period: Wash out period: F/u duration: 12 wk (also at end of open label study of 32 wks) | Primary outcome results: IIEF, Q3/ Q4 mean (sd) score: Baseline (IG=CG): 2 (0.1)/ < 2 (0.1) post tx: 4 (0.1) vs. 2 (0.1)/ 4 (0.1) vs. 1.8 (0.1) IIEF-EF, mean score: 22 vs. 12, p<0.001 Successful attempts of sexual intercourse (%): 69 vs. 22 Mean n of successful attempts in last 4 wks: 6 vs. 1.5 Improved erection, n (%): 101 (74) vs. 23 (19), p< 0.001 Other outcomes assessed: IIEF, Q6, 7, 8, 13 and 14 (> in IG); SD (no change) Withdrawals/drop-outs/loss to f/u, n (%): 9 (6) vs. 13 (8), open label (n=225)= 18 (8) WDAE, n (%): TAE, n (%): in 5% or more of all IG vs. CG/ IG open label: headache 30(18) vs. 14 (6)/ 28 (12); flushing 30 (18) vs. 1 (1)/ 22 (10); dyspepsia 9 (6) vs. 4 (2)/ 12 (5); rhinitis 8 (5) vs. 1(1)/ 4 (2); visual disturbance 4(2) vs. 1 (1)/ 9 (4) SAE: NR Ascertainment of outcomes assessed: IIEF; questionnaire for clinical assessment of ED, & tx outcomes; self report by event log; GAQ
Goldstein (1998) ^33^ Funding source: Pfizer | N screened = NR N randomized = 861 Study I dose-response IG1, n = 316 CG1, n = 216 Study II dose-escalation IG2, n = 163 CG2, n = 166 ITT analysis used for primary outcome: yes Inclusion: men with ED of 6 mo or longer, in a stable relationship with a female partner for at least 6 mo Exclusion: penile anatomical defects, another sexual disorder; SCI; major psychiatric disorder, poorly controlled DM; peptic ulcer disease, hx of alcohol or substance abuse, major systemic abnormalities, recent stroke or MI; nitrate therapy | Age, mean: 58 (NR) Race: NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: (n/grp) NR Duration of ED: NR, at least ≥ 6 mos. Underlying disease (%): 100 ED Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | Study I dose-response IG: oral sildenafil CG: oral placebo IG: Dose: 25 or 50 or 100 mg Duration: 12 wks Frequency: NR Compliance: NR CG: placebo (same as IG1) Study II dose-escalation: IG1: oral sildenafil CG: oral placebo IG1: Dose: 50 mg (dose could be doubled or reduced by 50% at f/u) Duration: 24 wks Frequency: NR Compliance: NR CG: placebo (same as IG1) Run In period: NR Wash out period: NR F/u duration: dose-response 12 wks dose-escalation 24 wks | Primary outcome results: IIEF, % increase from baseline in IG vs. CG: Q3, successful penetration Study I: 60 (25 mg), 84 (50 mg), 100 (100 mg) vs. CG 5 (p < 0.001); Study II, 95 vs. 10 (p< 0.001) Q4, maintaining erection Study I: 121 (25 mg), 133 (50 mg), 130 (100 mg) vs. 24 (p < 0.001); Study II: 140 vs. 13 (p< 0.001) All domains Study I & II: IG sign. higher with each dose vs. CG (p< 0.001) GEQ, % increase from baseline Study I: 56 (25 mg), 77 (50 mg), 84 (100 mg) vs. CG 25 (p<0.001) Study II: 74 vs. 19 (p< 0.001) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE: NR (AE in IG included headache, flushing, dyspepsia, transient visual disturbances) SAE: NR Ascertainment of outcomes assessed: IIEF; GEQ
Gómez (2002) ^34^ Funding source: Pfizer Inc. | N screened = NR N randomized = 159 IG, n = 76 CG, n = 82 ITT analysis used for primary outcome: Y Inclusion: men 18 or older; with ED for 6 mo or longer; in stable relationship with female partner for at least 6 mo Exclusion: genital anatomic deformity; hyperprolactinemia; low free T level; uncontrolled psychiatric disorders; alcoholism or substance abuse; hx of major hematological, renal or hepatic abnormality; uncontrolled DM; untreated proliferative diabetic retinopathy; hx of stroke, MI or CVD in last 6 mo; hypotension; known hx of retinitis pigmentosa; medication causally associated with ED; taking androgens, trazodone, nitrates (or nitric oxide donors); used vacuum devices, IC injection or any other ED tx | Age, mean (sd): 58 (11) vs. 55 (12) y Race, n (%): White 20 (13) Black 4 (2.5) Hispanic (mistizo) 123 (77) Other 11 (7) Co-morbidities: Hypotension 25 (33) vs. 17 (21) DM 13 (17) vs. 9 (11) Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 3 (0.4–12) y Underlying disease: NR Psychogenic ED, n (%): 10 (13) vs. 16 (20) Physiologic ED, n (%): IG1 48 (63) vs. 44 (54) Mixed ED, n (%): 18 (24) vs. 22 (27) | IG: Sidenafil CG: placebo IG: Dose: 50 mg; titration to 25 or 100 mg Duration: 12 wk Frequency: NR Compliance (%): NR CG: Dose: placebo Duration: 12 wk Frequency: NR Compliance (%): NR Run In period: 4 wk Wash out period: NA F/u duration: 12 wk | Primary outcome results: IIEF, change in mean score (approximate values from figure): Q3: 1.6 vs. 0.8 Q4: 1.8 vs. 0.8 EF: pre=13.6; post 22.1 vs. 18.4 OF: pre=6.9; post: 8.4 vs. 7.7 SD: pre=7; post 7.3 vs. 7.1 IC s: pre=7.4; post 10.8 vs. 9.4 OS: pre=4.6; post: 7.5 vs. 6.3 GAQ, % yes: 77 vs. 46 Successful intercourse attempts (last 4 wks), %: 65 vs. 35 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 12 (16) vs. 10 (12) WDAE, n (%): 1 syncope (1) vs. 0 TAE: pts with at least one AE=39 (51) vs. 27 (33); including headache 19 (25) vs. 10 (12); flushing 9 (12) vs. 6 (7); dyspepsia 5 (7) vs. 0; rhinitis 5 (7) vs. 1 (1); abnormal vision 5 (7) vs. 4 (5); conjuctivities 3 (4) vs. 0; diarrhea 3 (4) vs. 2 (2); chromatopsia 2 (3) vs. 0; palpitation 1 (1) vs. 2 (2); dizziness 0 vs. 3 (4); gastritis 0 vs. 2 (2); also laboratory abnormalities elevated blood urea nitrogen level in 4 (10) vs. 1 (1), elevated creatinine level in 3 (8) vs. 0; SAE: 0 Ascertainment of outcomes assessed: IIEF (EF=1–5,15), event log on sexual function
Gopalakrishnan (2006) ^35^ Funding source: Christian Medical College grant; Sun Pharmaceuticals provided the medication | N screened = 150 (40 were identified with ED) N randomized = 32 (randomized two way cross over) IG/CG, n = 32 ITT analysis used for primary outcome: yes Inclusion: married men with schizophrenia or delusional disorder on current tx; with ED Exclusion: regular use of nitrates, anticoagulants, or aspirin 2 wks prior to study entry; comorbid depressive syndrome; tx with antidepressants; alcohol or other substance dependence; hx of use of sildenafil citrated and continued use of other measures to improve ED | Age, mean (sd): 35.1 (5.5), range 24–45 y Race: NR Co-morbidities, n (%): paranoid schizophrenia 20 (62.5); catatonic schizophrenia 1 (3), undifferentiated schizophrenia 5 (16), delusional disorder 3 (9.3), Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: all pts on chlorpromazine equivalents dose 556.3 (198.6) range 200–1000 mg; mean dose of trihezyphenidyl 1.2 mg/d; 3 pts also on diazepam Duration of ED: NR Underlying disease, n (%): as in comorbid conditions Psychogenic ED, n (%): 10% Physiologic ED, n (%): 0 Mixed ED, n (%): NR | IG: Sildenafil CG: Placebo IG: Dose: 25 mg titrated to 50 mg based on efficacy outcomes at 1st wk Duration: 2 wks Frequency: up to 1/d Compliance: 100% CG: Dose: NA Duration: 2 wks Frequency: as IG Compliance: 100% Run In period: NR Wash out period: none F/u duration: end of each 2 wks period | Primary outcome results: N of grade 3 or 4 erections, mean (sd) combined for two wks of tx: 6.52 (3.92) vs. 3.32 (3.5); P< 0.001 duration of erection, mean (sd): 3.38 (2.25) vs. 2.20 (2.14) min, P<0.055 Combined N of satisfactory intercourse attempts, mean (sd): 5.29 (3.84) vs. 2.45 (3.33); P<0.001 Other outcomes assessed: tx interaction effects (NS) Withdrawals/drop-outs/loss to f/u, n (%): 1(3) WDAE, n (%): 0 TAE: 13 (41) vs. 3 (9.3) AEs, n (%): nasal congestion 4 (12.5) vs. 0; headache 3 (9.4) vs. 1 (3.1); loss of appetite 1 (3.1) vs. 0; retarded ejaculation 2 (6.3) vs. 1 (3.1); dyspeptic symptoms 1 (3.1) vs. 1 (3.1); giddiness 1 (3.1) vs. 0; rash 1 (3.1) vs. 0 SAE, n (%): NR Ascertainment of outcomes assessed: pts log
Hartmann (1999) ^36^ Funding source: NR | N screened = NR N randomized = 315 IG, n = 159 CG, n = 156 ITT analysis used for primary outcome: NR Inclusion: men 18 or older with documented diagnosis of ED for 6 mo or longer Exclusion: other sexual disorders, high serum PRL levels, low levels of free testosterone. Hx of renal, hepatic, haematological or bleeding disorders. Stroke or myocardial infarction ≤ 6 mons, poorly controlled diabetes, retinitis pigmentosa, treatment with androgens, trazadone, nitrates, nitrogen oxide donors | Age, mean: IG1: 54 CG: 55 Race (%): NR Co-morbidities (unrelated to disease): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): IG1: 5 CG: 5 Underlying disease: NR Psychogenic ED: 50 Physiologic ED, %: 46 Mixed ED, %: 54 Unknown: 3 vs. 6% | IG: sildenafil CG: oral placebo IG1: Dose: 25 mg option to titration to 50 or 100 mg Duration: 26 wks Frequency: as needed Compliance (%): NR CG: Dose: NA Duration: 26 wks Frequency: as IG Compliance (%): NR Run In period: NR Wash out period: NR F/u duration (both on and off treatment): NR Other: Final doses: 25 m: in 25% 50 mg in26% 100 mg in 49% | Primary outcome results: IIEF, Q7, mean: pre= 2.0; post tx: 3.6 vs. 2 IIEF, Q3, and 4: as Q7 GEQ, % improved: 79% vs. 23% Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 13 (8) vs. 0 WDAE, n (%): 8 (5) vs. 0 TAE: NR; most common AE reported headache, flushing, dyspepsia, rhinitis, respiratory tract infection (could not be extracted from table, bad scan); visual disturbances NR (1) vs. 0 SAE: NR Ascertainment of outcomes assessed: IIEF Q3, 4, 7, 13, and GEQ, Patient logbook
Heiman (2007) ^37^ Funding source: Pfizer Inc. | N screened = NR N randomized = 180 IG, n = 86 CG, n = 94 ITT analysis used for primary outcome: yes (n=85 vs. n=91) Inclusion: men 21 y or older with ED (score of 21 or less on Sexual Health Inventory for Men) and in stable relationship with female partner; with satisfactory sexual intercourse of 50% or less as reported by their female sexual partner Exclusion: couple with sign. dyspareunia or lifelong sexual dysfunction or men with more than six doses of any ED tx including PDE-5 inhibitor within 6 mo; use of nitrates, nitric oxide donors; medical or psychological conditions (i.e. CV, arthritis, hx of retinitis pigmentosa) | Age, mean (range): 58 (30–86) y Race: White 79%; Black 7%; Asian 2%; other 12.5% Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: current smokers 15% vs. 19% (43% never smoked) Body weight: NR | Concomitant medications, n (%): NR Duration of ED, mean (range): 4.7 (0.2–21.6) vs. 6.1 (0.1–34.7) y Underlying disease, n (%): NR Psychogenic ED (%): 16 vs. 12 Physiologic ED (%): 59 vs. 62 Mixed ED (%): 24 vs. 27 Other: IIEF baseline score, mean= 46.3 vs. 48.8; EF domain=13.2 vs. 12.6; OF domain= 5.6 vs. 5.5; SD domain=6.3 in both grps; IcS=6.7 vs. 6.1; OS=5; Q7=2.3 vs. 2.1 | IG: Sildenafil CG: Placebo IG: Dose: flexible dose 25, 50, and 100 mg Duration: 12 wks Frequency: as needed, 30 min to 1 hr prior to sexual activity Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: 2 wks Wash out period: NA F/u duration: 12 wks | Primary outcome results: IIEF, change from baseline mean (SE): EF domain: 8.9 (1) vs. 3.4 (1) OF domain: 1.5 (0.4) vs. 0.9 (0.4) SD domain: 0.4 (0.2) vs. 0.1 (0.2) ICS domain: 2.1 (0.3) vs. 0.8 (0.3) OS domain: 2.1 (0.3) vs. 0.8 (0.3) Q7: 1.5 (0.2) vs. 0.3 (0.2) GEQ, % improved (95% CI): GEQ-1: 69 (57–79) vs. 25 (16–36) GEQ-2: 71 (60–80) vs. 30 (20–41) Other outcomes assessed: responses in partner; EDIT scores, SEAR Withdrawals/drop-outs/loss to f/u, n (%): 21 (12) WDAE, n (%): 0 TAE, n (%): reported as tx related AE: 29 in 18 (21%) vs. 11 in 10 (11%) of pts; including one severe case of rhinitis in IG, and one severe headache in CG Most common AE: headache, vasodilatation, rhinitis, dyspepsia, and abnormal vision or chromatopsia (n=3 vs. 1) SAE, n (%): 0 Ascertainment of outcomes assessed: EDITS; IIEF; Self-Esteem And Relationship (SEAR)
Herrmann (2006) ^38^ Funding source: Pfizer Inc. | N screened = 16 (recruitment stopped; difficult recruitment due to concurrent release of vardenafil and tadalafil) N randomized = 12 IG, n = 8 CG, n = 4 ITT analysis used for primary outcome: NR Inclusion: men with moderate to severe ED despite an adequate sildenafil trial, of max 100 mg (ED defined as IIEF score of 16 or less); with serum low density lipoprotein (LDL) cholesterol 100 mg/dL or higher Exclusion: hx of Psychogenic ED; severe endocrinopathy including diabetics with neuropathy, recent suregery including prostatatectomy; acute | Age, mean (sd): 58 (13) y Race: NR Co-morbidities, n (%): DM 12% vs. 25%; elevated cholesterol 10 (83); hypertension 4 (33) Previous ED treatment: Smoking status: 38% vs. 75% Body weight: NR Other: LDL cholesterol 139 (19) vs. 146 (10) mg/dL; N of pts with DM is not consistently reported (text: n=2, 17% in total) | Concomitant medications, n (%): Duration of ED: 4.2 (4.8) vs. 2.6 (2.9) y Underlying disease, n (%): as co-morbidities Psychogenic ED, n (%): NR Physiologic ED, n (%): all Mixed ED, n (%): NR Other: IIEF- EF domain at baseline, mean (sd) 10.2 (7.4) vs. 4 (3.6) | IG: Sildenafil + Atoravastatin CG: Sildenafil + placebo IG: Dose: Sildeanfil 100 mg up to once/d; Atorvastatin 80 mg/d Duration: 12 wks Frequency: once /d (each medication) Compliance: CG: Dose: sildenafil as IG + Atorvastatin placebo tablets Duration: 12 wks Frequency: as IG Compliance: Run In period: NR Wash out period: NR F/u duration: 12 wks | Primary outcome results: IIEF, Q-15, mean (sd): Baseline 10.3 (7.4) vs. 4 (3.6) Post tx (12 wks): 18 (10.6) vs. 12.3 (12.4); influenced by single outlier increasing from 9 to 29; increase in post tx score excluding this pts = 4.3 (sildenafil grp ▴ by 7.8) IIEF-Q6: improved in 100% vs. 25% GAQ-1, % improved: 62.5% vs. 25% GAQ-2, % improved: 62.5% vs. 25% GAQ, % improved: 62.5% vs. 25% Other outcomes assessed: LDL cholesterol levels ▾ from 135 (19) to 78 (20) mg/dL, or 43% with Atorvastatin vs. from 146 (10) to 139 (24) in placebo Withdrawals/drop-outs/loss to f/u, n (%): 0 WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: IIEF; Blood analysis for lipid profile
Hussain (2001) ^39^ Funding source: Pfizer | N screened = 24 N randomized = 17 (crossover design) IG/CG, n = 24 ITT analysis used for primary outcome: N Inclusion: Parkinson's (PD) disease or multiple system atrophy (MSA); resting and standing SBP 90–180 mm hg, and DBP 50–110 mm Hg, on tx if necessary Exclusion: no stable sexual partner; penile deformity; other sexual or psychological disorder; known hx of alcohol or drug dependence; DM; retinitis pigmentosa; hx of stroke or MI; sign cardiac hx; nitrate therapy; lipid abnormality; thyroid, renal, hepatic or hematologic dx | Age, median (range): PD 61 (48–68) MSA 54 (46–61) y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): NR Underlying disease, n (%): PD 12 (97) MSA 6 (33) Psychogenic ED: 0 Physiologic ED, %: 100 Mixed ED: 0 | IG: sildenafil citrate CG: placebo IG: Dose: 50 mg with option ot titrate to100 or 25 mg Duration: 10 wks Frequency: up to once/d, 1 hr before sexual activity Compliance: NR CG: Dose: placebo, titration option as IG Duration: 10 wks Frequency: as IG Compliance: NR Run In period: 4 wk Wash out period: None F/u duration: 20 wk (cross over at 10 wks without washout) | Primary outcome results: (CG, n=16; IG n=14) IIEF-Q3, mean: 3 vs. 2 IIEF-Q4, mean: 4 vs. 1.4 Quality of life questionnaire: Whole life, mean: 4.9 vs. 4.7 Sex life, mean: 4.2 vs. 2.2 Other outcomes assessed: Partner questionnaire Withdrawals/drop-outs/loss to f/u, n (%): 8 (27) including one pts in PD due to lack of efficacy, pt chose to return to IC injections. WDAE: 3 (12.5) in (50% of MSA pts) TAE: NR; 3 events of orthostatic hypotension (fall in standing BP), feeling unwell and unable to stand in IG (MSA) SAE: NR Ascertainment of outcomes assessed: IIEF, quality of life (0–5 for each questions)
Incrocci (2001) ^40^ Funding source: Pfizer B.V., The Netherlands | N screened = 82 N randomized = 60 (cross-over) IG/ CG = 30 ITT analysis used for primary outcome: No Inclusion: men with progressive ED after 3-dimensional conformal external beam radiotherapy (3D-CRT) for prostate who agreed to perform sexual activity at least once/ wk; in a stable relationship Exclusion: hx of MI or CVA, prior radical prostatectomy; post-radiotherapy rise in PSA; use of nitrates or hormone therapy | Age, mean: 68 y Race (%): NR Co-morbidities (unrelated to disease): NR Previous ED treatment: None Smoking status: NR Body weight: NR Other: PSA/micrograms, mean (range): 8.5 (1–227) litre | Concomitant medications: NR Duration of ED, mean (range): time from radiation to trial 39 (15–55) mo Underlying disease (%): Hypertension: 10%; DM 3%; Transurethral resection of the prostate: 18% Psychogenic ED: NA Physiologic ED: 100% Mixed ED: NA | IG: sildenafil CG: placebo IG1: Dose: 50 mg with option to increase to 100 at 2 wks, or decrease to 25 mg in case of AE Duration: 6 wks Frequency: at least 1/wk, up to 1/d Compliance (%): 100% CG: Dose: NA Duration: 6 wks Frequency: at least 1/wk, up to 1/d Compliance (%): 100% Run In period: 4 wks Wash out period: NR F/u duration: 12 wks (assessments at end of each 6 wks period) Other: 90% patients ▴ dose to 100 milligrams, 0% ▾ to 25 mg | Primary outcome results: IIEF baseline mean; post tx mean (sd) IG vs. CG Q1: 1.7; post 2.9 (1.6) vs. 1.8 (1.1) Q2: 1.5; post 2.8 (1.8) vs. 1.5 (1.1) Q3: 1.5; post 2.8 (1.7) vs. 1.6 (1.1) Q4: 1.3; post 2.6 (1.7) vs. 1.5 (1.0) Q5: 1.6; post 2.8 (1.1) vs. 1.8 (1.4) Q6: 1.2; post 2.8 (1.1) vs. 2.4 (1.0) Q7: 1.9; post 2.7 (1.6) vs. 1.9 (1.3) Q8: 1.6; post 2.8 (1.4) vs. 1.9 (1.1) Q10: 2.1; post 3.0 (1.6) vs. 2.4 (1.6) Q11: 2.8; post 3.0 (1.1) vs. 2.8 (1.2) Q12: 2.7; post 3.0 (1.0) vs. 2.6 (1.0) Q13: 2.3; post 3.0 (1.4) vs. 2.3 (1.2) Q14: 2.7; post 3.2 (1.4) vs. 2.8 (1.4) Q15: 2.1; post 3.0(1.1) vs. 2.4 (1.3) GEQ, % with improved: 45 vs. 8 Successful intercourse %: 55 vs. 18 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: AEs (%)= headache: 42 vs. 15; flushing: 13 vs. 2; myalgia 15 vs. 13; nasal congestion 22 vs. 12; dyspepsia 32 vs. 8; dizziness 17 vs. 10 SAE: 0 Ascertainment of outcomes assessed: IIEF; GEQ
Incrocci (2003) ^41^ Funding source: Pfizer B.V. | N screened = NR N randomized = 60 (6 wk cross over); also open label phase IG, n = 30 CG, n = 30 ITT analysis used for primary outcome: No Inclusion: progressive ED after 3 dimensional external beam radiotherapy for prostate cancer; normal EF before radiotherapy; in stable relationship Exclusion: use of nitrates | Age, mean (range): 68 (56–79) y Race (%): NR Co-morbidities: diabetes and/or hypertension 13% Previous ED treatment: NR Smoking status: NR Body weight: NR Other: Mean interval between completion of radiotherapy and study initiation = 39 mo (range 15–55) | Concomitant medications: NR Duration of ED (yr): NR Underlying disease (diagnosis) (N or % of diseased/ grp): NA Psychogenic ED: NR Physiologic ED: N Mixed ED: NR | IG: sildenafil citrate orally CG: placebo orally IG: Dose: 50 mg for first 2 wk; option to increase to 100 mg for next 4 wk Duration: 6 wk Frequency: up to once/ d, 1 hr before sexual activity at least once/ wk Compliance: NR CG: Dose: placebo Duration: 6 wk Frequency: as IG Compliance: NR Run In period: 4 wk Wash out period: None F/u duration: 6 and 12 wks (last fu at 2 y) | Primary outcome results: Mean IIEF mean score (sd), IG vs. CG: Q1- pre: 2 (2); post: 3 (2) vs. 2 (1) Q2- pre: 2 (2); post: 3 (2) vs. 2 (1) Q3=Q4=Q5=Q7: pre: 2 (1); post: 3 (2) vs. 2 (1) Q6- pre: 1 (1); post: 3 (1) vs. 2 (1) Q9- pre: 2 (2); post 3 (2) vs. 2 (1) Q10- pre: 2 (2); post: 3 (2) vs. 2.5 (2) Q11- pre: 3 (1); post: 3 (2) vs. 3 (1) Q12- pre: 3 (1); post: 3 (1) vs.2.6 (1) Q13- pre: 2 (1); post: 3 (1) vs. 2 (1) Q14- pre: 3 (1); post: 3 (1) vs. 2.8 (1) Q15- pre: 2 (1); post: 3 (1) vs. 2.3 (1) GAQ1, %: 61 vs. NR GAQ2, %: 65 vs. NR Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: NR; % with AE (IG vs. CG/ IG open label): headache 42 vs. 15/17; flushing 13 vs. 2/11; myalgia 15 vs. 13/6; nasal congestion 22 vs. 12/11; dyspepsia 32 vs. 8/24; vision disturbances 17 vs. 8/13; dizziness 17 vs.10/6 SAE: 0 Ascertainment of outcomes assessed: IIEF, GEQ, 1 and 2
Kaplan (2007) ^42^ Funding source: Pfizer (conflict of interest reported) | N screened = N randomized = 62 (single center; open label) IG1, n = 21 IG2, n = 20 CG, n = 21 ITT analysis used for primary outcome: yes Inclusion: men with self reported ED and untreated LUTS Exclusion: criteria complied with contraindication of both drugs | Age, mean (sd): 63.4 (7.6) y Race: NR Co-morbidities, %: DM 27.4; hypertension 25.8%; Ischemic heart disease 14.5 Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: 24.8 (4.3) mo Underlying disease, n (%): Psychogenic ED, n (%): NR Physiologic ED, n (%): 100% Mixed ED, n (%): NR | IG1: Sildenafil IG2: Alfuzosin CG: Sildenafil + Alfuzosin IG1: Dose: 25 mg Duration: 12 wks Frequency: one/d Compliance: IG2: Dose: 10 mg Duration: 12 wks Frequency: one/d Compliance: NR CG: Dose: combination of IG1 and IG2 doses Duration: 12 wks Frequency: one of each/ d Compliance: NR Run In period: NR Wash out period: NR F/u duration: 12 wks | Primary outcome results: IIEF mean (sd) Q3: baseline 2.2 (0.9); % improvement from baseline 41.7% vs. 27.3% vs. 65.2% Q4: baseline 2.3 (1.1); % improvement from baseline 59.1% vs. 33.3% vs. 68.2% EF domain: baseline 15.9 (3.2); post tx IG= 21.4 (5.7) vs. IG2=20.3 (5.2) vs. IG3=25.7 (4.9); % change from baseline: 49.7% vs. 16.7% vs. 58.6% Other outcomes assessed: IPSS; PVRU volume Withdrawals/drop-outs/loss to f/u, n (%): 7 (11) WDAE, n (%): total 7 (11); 2 (10) vs. 2 (10) vs. 3 (14) TAE: NR; AE flushing and dyspepsia in sildenafil grp vs. dizziness in Alfuzosin vs. dizziness in combination grp SAE: 0 Ascertainment of outcomes assessed: IIEF-EF; International Prostate Symptom Score (IPSS); post-void residual urine (PVRU) volume
Katz (2005) ^43^ Funding source: Pfizer | N screened = 202 N randomized = 137 (parallel design) IG, n = 63 CG, n = 74 Intention to Treat (ITT): Yes (IG, n=60; CG n=72) Inclusion: men 18 y or older, with ED, (Sexual Health Inventory for Men score of 21 or greater), & documented evidence of stable coronary heart failure (CHF); naïve to sildenafil (discontinue at least by screening visit) Exclusion: hypotension, high cardiac risk, CHF secondary to hypertrophic cardiomyopathy; hx or myocarditis or implantable defibrillator firing 6 mo prior to entry; use of organic nitrates, drugs that inhibit cytochrome P450 (i.g. ritonavir) Data reported as IG vs. CG (unless otherwise indicated) | Age, mean (range): all, 60 (38–83) y Race (%): NR Co-morbidities: all pts had one or more conditions including diabetes, hypercholestrrolemia, hypertension, ischemic heart dx, past coronary bypass Previous ED treatment: NR Smoking status: 22% in both grps; 19% vs. 33% were ex-smokers | Concomitant medications: ACE inhibitors; angiotension II receptor antagonist (29% vs. 15%); β blockers; loop diuretics, cardiac glycosides, oral anticoagulants, analgesics fro mild to moderate pain (11% vs. 22%) Duration of ED, mean (range): 5 (0.1–22) y Underlying disease: CHF, duration of 6 (0.27–31.7) vs. 4.8 (0.03–22.2) y Psychogenic ED, %: 2 vs. 1 Physiologic ED, %: 57 vs. 56 Mixed ED, %: 41 vs. 43 | IG1: Sildenafil CG: placebo IG1: Dose: 50 mg, adjusted to 25 or 100 mg based on pts tolerability & efficacy Duration: 12 wk Frequency: NR Compliance (%): NR CG: Dose: NR Duration: as IG Frequency: NR Compliance (%): NR Run In period: 2 wks Wash out period: NA F/u duration: 12 wks | Primary outcome results: Baseline (mean); post tx (least square mean) scores: Q3 (improved erections): pre=1.7; post: 3.7 vs. 2.8 (p=0.0003); [74% of pts vs. 18% improved, (<0.002)] Q4 (improved intercourse), mean score: pre=1.4 post: 3.3 vs. 2.4 (p = 0.0012); [68% vs. 16% improved (p<0.002)] IIEF, EF: pre=33; post 71 vs. 53 IIEF Q9, 10: pre=45; post 77 vs. 67 IIEF Q11, 12: pre=61; post 69 vs. 63 IIEF, Q6, 8: pre= 35; post 69 vs. 55 IIEF, Q13, 14: pre=39; post: 79 vs. 58 Intercourse success (%): 53 vs. 20, Improved erection, %: 74 vs. 18 Improved intercourse, %: 68 vs. 16 Other outcomes assessed: IIEF Q 5–12; GEQ; life satisfaction check list; EDITS Withdrawals/drop-outs/loss to f/u: 20 (16) vs. 10 (14) WDAE: 2 (3) vs. 2 (3) TAE: (% of pts) 60% vs. 48% (headache 13% vs. 3%, also respiratory tract infection, asthenia, peripheral edema, rhinitis, back pain, rash, pain in both grps; vasodilatation; ▴ cough, neoplasm, chromatopsia only in IG) SAE: 3% vs. 5% Ascertainment of outcomes assessed: self administered IIEF; GEQ, EDITS
Kongkanand (2003) ^44^ Funding source: Pfizer | N screened = NR N randomized = 125 IG, n = 63 CG, n = 62 ITT analysis used for primary outcome: yes (n=125) Inclusion: men ED ≥ 6 mo, stable heterosexual relationship ≥ 6 mo. Exclusion: Genital deformities, SCI, co-existing sexual disorders, raised serum PRL levels or low free T level, major psychiatric disorder, hx of alcohol or substance abuse; major haematological, renal or hepatic dx, DM; poorly controlled or associated with untreated proliferative retinopathy; hx of stroke or MI≤ 6 mo; hypotension or other sign CV dx, hx of retinitis pigmentosa; taking drugs associated with ED; use of vacuum devices or other tx for ED. | Age, mean (range): 54 (31–76) vs. 56 (26–77) Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status, n (%): Smokers: 11 (18) vs. 9 (15) Body weight, mean: 68 vs. 69, range 54–90 kg | Concomitant medications: NR Duration of ED, n (%): ≤ 2 y: 42 (67) vs. 35 (57); >2 to ≤ 5 y: 15 (24) vs. 20 (32) > 5 y: 6 (10) vs. 7 (11) Underlying disease: NR Psychogenic ED: 7 (11) vs. 6 (10) Physiologic ED, n (%): 41 (65) vs. 39 (63) Mixed ED, n (%): 15 (24) vs. 17 (27) | IG: sildenafil citrate CG: placebo IG: Dose: initially 50 mg for 2 wks, then option to titrate up to 100 mg or down to 25 mg Duration: 12 wks (median= 84 d) Frequency: as needed Compliance (%): 92 CG: Dose: NA Duration: 12 wks (median=83 d) Frequency: as needed Compliance (%): 84 Run In period: 4 wks Wash out period: NR F/u duration: NR | Primary outcome results: IIEF, Q3 frequency of penetrate, mean: baseline= 2; post tx: 4 vs. 3 IIEF, Q4, frequency of maintaining erection after penetration, mean: baseline=2; post tx: 4 vs. 3 IIEF, EF, mean: baseline=13; post tx: 22 vs. 17 IIEF, OF, mean: baseline=5, post tx: 8 vs. 5 IIEF, SD, mean: baseline=5, post tx: 7 vs. 6 IIEF, intercourse satisfaction, mean: baseline=6; post tx 11 vs. 9 Intercourse success, %: 66 vs. 32 GAQ, % yes: 82 vs. 36 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 1 (2) in CG WDAE: 0 TAE, n (%): 19 (30) vs. 7 (11); including: flushing = 14%; headache = 6%; dizziness = 6%; laboratory abnormalities: included raised levels of eosinophils, total bilirubin, and blood urea nitrogen 1 (2) in IG; 4 sign laboratory abnormalities in n=2 in CG SAE: 0 Ascertainment of outcomes assessed: IIEF, pts event log, GAQ, physical exam
Koulikov (2007) ^45^ Funding source: Pfizer Inc. | N screened = 82 N randomized = 60 (crossover) IG, n = 30 CG, n = 30 ITT analysis used for primary outcome: NR Inclusion: men between 45 and 75 y and older with ED and various urological complaints (LUTS, ED and nephrolithiasis), and diagnosis of ADAM (direct Tb less than 0.7 gm/l were defined as hypogonadal) Exclusion: penile anatomical defects; uncontrolled medical illness or psychological disorders; pts with high cardiac risk (according to Princeton guideline); or regular or intermittently use of drugs that alter androgen metabolism or hx of PDE-5i | Age, mean (SEM): 63.3 (7.85), range 47–75 y Race: NR Co-morbidities, n (%): hypogonadal 27 (48), low total T in 13/27 Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): various urological reasons Psychogenic ED, n (%): NR Physiologic ED, n (%): 100% Mixed ED, n (%): NR | IG: Sildenafil CG: Placebo IG: Dose: 50 mg, titrated to 100 mg after 2 wks (if no improvement in EF with at least 3 pills) Duration: 1 mo Frequency: one pill 30–60 min before planned sexual activity up to once/d Compliance: NR CG: Dose: NA Duration: 1mo Frequency: as IG Compliance: NR Run In period: NR Wash out period: NR F/u duration: at end of each tx period (each study period was 3 mo; washout and run in is not reported). | Primary outcome results: Improvement in EF, mean (SEM): 39 (1.9) vs. 52.7 (2) Improvement in IIEF-EF from baseline, mean (SEM): Normal men: 18.4 (3.6) Hypogonadal men: 6.7 (2.7) (no difference in baseline scores of EF between normal and hypogonadal men) Other outcomes assessed: FSH, LH, Total T, and Tb (numerical data NR) Withdrawals/drop-outs/loss to f/u, n (%): 19 (63.3) vs. 12 (40) WDAE, n (%): 1 (3.3) vs. 1 (3.3) TAE, n (%): difficulty in controlling BP 0 vs. 1 (3.3); non-Q MI 1(3.3) before ingestion of first tablet vs. 0 SAE, n (%): NR Ascertainment of outcomes assessed: serum hormone analysis
Levinson (2003) ^46^ Funding source: Pfizer | N screened = 279 N randomized = 279 IG, n = 128 CG, n = 126 ITT analysis used for primary outcome: Yes Inclusion: men 18 or older with ED of at least mo in duration; in a stable relationship Exclusion: penile abnormalities; SCI, concomitant tx with nitrates, endocrine anomalies; major haematological, renal, or hepatic dx, CV dx for less than 6 mo, poorly controlled DM, concomitant use of other ED therapies, hx of alcohol or substance abuse, major psychiatric disorder | Age, mean (range): 52 (26–75) vs. 52 (28–76) Race (%): Asian: 6 vs. 7; Black: 2 vs. 2 Mediterranean: 52, vs. 48 White: 40, vs. 42 (all from Egypt and South Africa) Co-morbidities (%): DM: 27; hypertension: 24; unspecified visual disorders: 14; hypercholesterolemia: 6 Previous ED treatment: NR Smoking status (%): 20 vs. 29 Body weight: NR | Concomitant medications, %: Antihypertensives: 24% Anitdiabetic drugs: 24% Anti-inflamatory agents: 15% Antibiotics: 11% Diuretics: 10% Drugs for hyperlipidemia: 8% Duration of ED, mean: 3.7 vs. 4.4 y Underlying disease: NR Psychogenic ED (%): 26 vs. 29 Physiologic ED (%): 38 vs. 43 Mixed ED (%): 37 vs. 29 | IG: sildenafil citrate CG: placebo IG: Dose: 50 mg, titrated to 100 or 25 mg Duration: 12 wks Frequency: up to once/d (total dose=41) Compliance (%): NR CG: Dose: NA Duration: 12 wks Frequency: up to once/d (total dose=33) Compliance (%): NR Run In period: 4 wks Wash out period: NR F/u duration: NR Other: pts information regarding dose of sildenafil used at the end of tx period, n: 25 mg: 7 vs. 1 50 mg: 32 vs. 5 100 mg: 86 vs. 114 | Primary outcome results: Values are approximate (extracted from figure), mean: IIEF, Q3: baseline =2; post tx: 4 vs. 2.5 IIEF, Q4: baseline =2; post tx: 4 vs. 2 IIEF- Q7: baseline= 2; post tx: 4 vs. 2.3 GAQ, % yes: 74 vs. 27 Intercourse success, %: 69 vs. 28 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 15 (12) vs. 13 (10); including 0 vs. 4 (3) due to insufficient tx response WDAE, n (%): 3 (2) vs. 0 TAE, n (%): in at least 5%of pts= 63 (49) vs. 45 (36); including headache 26 (20) vs. 10 (8); dyspepsia 12 (9) vs. 1 (0.8); abnormal vision (chromotopsia) 10 (8) vs. 4 (3); flushing 8 (6) vs. 2 (2); rhinitis 7 (6) vs. 3 (2); flu syndrome) 5 (4) vs. 9 (7); CV events (including one re-infarction, and three pts with palpitations in IG and one hypertension in CG) 4 (3) vs. 1 (0.8) SAE: 3 (2) vs. 0; MI, accidental vertebral fracture, diverticulitis Ascertainment of outcomes assessed: physical exam, laboratory tests, questionnaires
Lindsey (2002) ^47^ Funding sources: Colorectal research fund, Pfizer | N screened = 43 N randomized = 32 IG, n = 14 CG, n = 18 (n=10 crossed over to open label sildenafil after placebo) ITT analysis used for primary outcome: No Inclusion: male, postoperative with ED and colorectal cancer Exclusion: pre-operative ED, medical contraindication to sildenafil | Age, median (interquartile range): 59.5 (51.1–64.9) vs. 58.7 (49.4–67.5) y Race (%): NR Co-morbidities (unrelated to disease): NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: 18 pts with total ED, 14 with partial | Concomitant medications: NR Duration of ED: NR [time since surgery, median (IQR)= 5.6 (3.3–7.7) y] Underlying disease, n (%): proctectomy for rectal cancer 12 (37.5); proctectomy for Inflammatory Bowel Diseases 20 (62.5); stoma 11 (34.3) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: sildenafil CG: placebo IG: Dose: < age 65 50 mg; ≥ 65 y old pts 25 mg, max dose of 100 mg. Duration: 4 wks Frequency: NR Compliance (%): 100% CG: Dose: NA Duration: 4 wks Frequency: NR Compliance (%): 100% Run In period: NR Wash out period: NR F/u duration: 4 wks (duration of open label trial NR) Other: n=13, and n=11 were dosed up to 50, and 100 mg sildenafil respectively | Primary outcome results: IIEF total score, mean: Baseline: 26.7 vs. 29.5 Post tx: 57.4 vs. 34.5 (post open label: 67 vs. 39.7) GEQ, % with improved erection: 78.6% vs. 16.7% Other outcomes assessed: Subanalysis by disease grp and severity of impotence was performed on n=24 who receive sildenafil either as primary or crossover tx Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE, n (%): 7 (50) vs. 4 (22), most common AE facial flushing followed by headache (46%, and 64% of pts on 50 and 100 mg respectively experienced AE at end of open label) SAE: 0 Ascertainment of outcomes assessed: GEQ, IIEF
Mahon (2005) ^48^ Funding source: Pfizer Inc. (study medication & placebo) | N screened = 41 N randomized = 16 IG/CG, n = 16 (cross over) ITT analysis used for primary outcome: NR (analysis for n=13) Inclusion: men 18 y or older with ED and renal failure (on peritoneal dialysis) Exclusion: cerebro-vascular event within the last 6 mo, severe hepatic impairment, presence of penile anatomic deformities, severe cardiac dx, or concomitant nitrate therapy | Age, mean (range): 53 (26–74) y Race (%): White 46%; Black 46%; Indian 8% Co-morbidities: NR Smoking: 8% smoked Previous ED treatment: NR Other: n=1 heavy drinker; n=8 social drinker (<3 to 4 units/d) | Concomitant medications: NR Duration of ED: 6 mo to 7 y Underlying disease: diabetes n=6 (46%); hypertensive (hypertensive nephropatny, diabetic nephropathy, focal segmental glomerulosclerosis, polycystic kidney disease) n=10 (77%) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: sildenafil (1st then swithced to placebo) CG: placebo (1st then switched to sildenafil) IG: Dose: 50 mg, titrated to 100 mg at wk 2 if no response was attained with the initial dose Duration: 4 wks Frequency: once/ d Compliance (%): 100% CG: Dose: 50 mg Duration: as IG Frequency: as IG Compliance (%): 100% Run In period: 4 wks Wash out period: none F/u duration: 12 wks (including the no treatment run-in period) | Primary outcome assessed: (some values extracted from figure and are approximate) IIEF-EF, mean score: pre: 6.7; post 20 vs. 12 IIEF-OF: pre: 3; post 6.5 vs. 3.8 IIEF- SD: pre: 5; post: 6.3 vs. 5.3 IIEF, ICs: pre: 2.8; post 9.8 vs. 5.7 OS: IG= 7 Q3 (ability to penetrate): post: 3.4 vs. 1.7 Q4 (maintaining erection): post: 3.2 vs. 1.6 GEQ, % improved: 75% vs. 28% PSV (20 min post PgE1 injection), median (range): 29.5 (7–66) m/s EDV (15 min post injection), median (range): 5 (0–13) m/s Other outcomes assessed: T levels, sex hormone binding globulin, PRL, luteinizing hormone, follicle stimulating hormone, HbA1C Withdrawals/drop-outs/loss to f/u: n=3 (1 died, reported unrelated to intervention) WDAE: 0 TAE: 1 headache in IG (no titration in this pts) SAE, n (%): 0 Ascertainment of outcomes assessed: self administered IIEF; GEQ; Doppler ultrasound
McVary (2007) ^49^ Funding source: Pfizer Inc. (two of the authors declare financial interest /relationship with Pfizer/ Lilly ICOS) | N screened = 683 N randomized = 370 (from 41 centres in US) IG, n = 189 CG, n = 181 ITT analysis used for primary outcome: yes Inclusion: men at least 45 y with ED, score of 25 or less on IIEF-EF domain, and lower urinary tract syndromes (LUTS) associated with prostatic hyperplasia, I-PSS score of 12 or greater Exclusion: confirmed or suspected prostate malignancy; urinary tract dx; hypotension, hypertension, orthostatic hypotension or sign CV dx, use of nitrates; pts with hepatic or renal dysfunction, poorly controlled DM or hx of retinitis pigmentosa, use of antimuscarinics was prohibited | Age, mean (sd): 60 (8.7) vs. 60 (8.5) y Race: White 82%; Black 11.5%; Asian 2%; other 4% Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: 5.7 (<1–25) vs. 5.6 (<1–35) y Underlying disease %: LUTS, 100% Psychogenic ED, n (%): 5 (3) vs. 8 (4) Physiologic ED, n (%): 113 (60) vs. 97 (54) Mixed ED, n (%): 71 (38) vs. 75 (42) Other: baseline IIEF-EF score, mean (sd): 13.4 (6.8) vs. 13.2 (6.6) | IG: Sildenafil CG: Placebo IG: Dose: 50 mg, titrated to 100 mg at 2 wks based on tolerability and efficacy (down to 50 mg if 100 mg was not toleated, and discountinued if 50 mg was not tolarable) Duration: 12 wks Frequency: once/d Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: Wash out period: F/u duration: 12 wks | Primary outcome results: IIEF-EF, mean IG vs. CG: Baseline= 13.4 vs. 13.2 12 wks: 23.5 vs. 15.9 IIEF-EF, LS mean change (95% CI): 9.17 (7.25, 11.09) vs. 1.86 (-0.03, 3.74) Other outcomes assessed: EDITS and SEAR questionnaire Withdrawals/drop-outs/loss to f/u, n (%): 21 (11) vs. 25 (13.8) WDAE, n (%): 10 (5) vs. 6 (3) TAE, n (%): 100 (53) vs. 78 (43); included headache, flushing dyspepsia and rhinitis in both grps SAE, n (%): 2 (1) vs. 3 (2); SAE included one case of moderated worsening of right knee arthralgia while on 100 mg sildenafil; and one case of severe acute cerebro-vascular stroke also on 100 mg sildenafil; no pts discontinued as result of SAE Ascertainment of outcomes assessed: IIEF; I-PSS; Qmax; SEAR; EDIT; BPHII and QOL
Melnik (2005) ^50^ Funding source: NR | N screened = 287 N randomized = 30 IG1, n = 10 IG2, n = 10 CG, n = 10 ITT analysis used for primary outcome: No Inclusion: men 25–50 y, with exclusive diagnosis of non-organic, psychogenic (according to IDC-10) mild to moderate ED for at least 6 mo in duration; in a heterosexual relationship for at least 1 y Exclusion: clinical or psychiatric disease, primary sexual disorder, penile anatomic defects; use of medication known to interfere with sexual function; physical limitations for use of sildenafil citrate; patients with drug or alcohol use; smoking Data reported as IG1 n=8 vs. IG2 n=6 vs. CG n=8 | Age, mean: 40 vs. 66 vs. 43 y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: baseline IIEF | IG1: Sildenafil + grp psychotherapy IG2: Sildenafil CG: grp psychotherapy IG1/IG2: Dose: 50 mg Duration: 6 mo Frequency: on demand Compliance: NR CG: Dose: NA Duration: 6 mo Frequency: time limited Compliance: NR Run In period: Wash out period: NR F/u duration: immediately after tx at 6 mo, and 3 mo post intervention at 9 mo | Primary outcome results: IIEF (ED severity) at baseline, % of pts: Score 11–16: n: 5 vs. 4 vs. 5 Score 17–26: (mild ED) 3 vs. 2 vs. 3 IIEF (ED severity) at 3 mo post tx, %: Score 11–16: 0 vs. 1 vs. 0 Score 17–26: 2 vs. 2 vs. 2 Score 26–30: 6 vs. 2 vs. 6 Severity of ED based on IIEF at 6 mo tx, %: Score 11–16: 0 vs. 1 vs. 0 Score 17–26: 4 vs. 3 vs. 2 Score 26–30: 4 vs. 2 vs. 6 IIEF total score, mean: Pre: 41 vs. 46 vs. 43 Post (6 mo): 58 vs. 49 vs. 62 9 mo post: 62 vs. 53 vs. 63, sign.higher mean scores in IG2 vs. CG, p<0.05 Sign.differences between IG1 and CG in remission of symptoms (EF 26 or higher), p= 0.0002 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, %: 20 vs. 40 vs. 20 WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: IIEF; clinical interview
Meuleman (2001) ^51^ Companion study ^36^ Funding source: NR | N screened = NR N randomized = 315 IG, n = 159 CG, n = 156 ITT analysis used for primary outcome: Yes Inclusion: men 18 or older, with clinical diagnosis of ED for at least mo; in stable relationship with female partner for more than 6 mo Exclusion: sign genital anatomical deformities (e.g. Peyronie's dx); primary diagnosis of other sexual disorders; hyperprolactinemia; hx of major haematological, renal or hepatic abnormalities; poorly controlled major psychiatric disorder; ED attributable to SCI; poorly controlled diabetes or untreated proliferative diabetic retinopathy; occurrence of CVD, stroke or MI within 6 mo before study; tx with anticoagulants, androgens, trazodone or nitrates | Age, mean (range): 55 (24–77) vs. 54 (23–82) y Race (%): NR Co-morbidities, n (%): Diabetes: 25 (16) vs. 24 (15); hypertension: 33 (21) vs. 30 (19); Ischemic heart dx 21 (13) vs. 10 (6); pelvic surgery 33 (21) vs. 27 (17) Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 4.8 (1–35) vs. 5 (1–27) y Underlying disease: NR Psychogenic ED: 50 (32) Physiologic ED, n (%): 46 (29) Mixed ED, n (%): 60 (38) vs. 54 (35) Other types of ED, n (%): 0 vs. 3 (2) | IG: Sildenafil citrate CG: Placebo IG1: Dose: 25 mg titrated to 50 mg 100 mg at any of 5 times during tx period Duration: 28 wk Frequency: once daily, one hr before sexual activity Compliance: NR CG: Dose: Placebo Duration: 28 wk Frequency: once daily, one hr before sexual activity Compliance: NR Run In period: 4 wk Wash out period: NA F/u duration: 12 wks and 26 wks post tx | Primary outcome results:IIEF- at 12 wks (values very close to 26 wks result), mean (SEM) IIEF, Q3=Q4: pre=2 (2); Post 2 (0.2) vs. 4 (0.2) IIEF, EF: pre=12 (0.7); Post tx: 13 (0.7) vs. 21 (0.7) IIEF, OF: pre=6 (0.3); Post 6 (0.3) vs. 8 (0.3) IIEF, IS: pre=7 (0.4); Post: 8 (0.3) vs. 11 (0.4) IIEF, OS: pre=5 (0.2); post: 5 (0.2) vs. 7 (0.2) IIEF, SD: pre=6 (0.2); Post: 6 (0.2) vs. 7 (0.1) Other outcomes assessed: event log reports; partner satisfaction Withdrawals/drop-outs/loss to f/u: 35 (22) vs.77 (49) stopped tx WDAE, n (%): 5 (3) vs. 1 (<1); headache (3) and colour tinge to vision, dizziness, diarrhoea, nausea, and intermittent stomach ache in IG, one headache in CG TAE, n (%): NR; most common: flushing, headache, dyspepsia, and rhinitis; abnormal vision in IG 2 (1), star vision, colour perception SAE, n (%): 8 (5) vs. 6 (4); two death in IG, one due to accident and one cardiac arrest 1 mo post last dose Ascertainment of outcomes assessed: IIEF; GAQ; diary log
Montorsi (1999) ^52^ Funding source: Pfizer Inc. | N screened = NR N randomized = 514 IG1, n = 128 IG2, n = 132 IG3, n = 127 CG, n = 127 ITT analysis used for primary outcome: yes Inclusion: men 18 or older, with at least 6 mo primary clinical diagnosis of ED Exclusion: SCI, hx of stroke or MI in the last 6 mo or longer, major hematologic, renal or hepatic abnormalities, receiving regular tx with nitrates; poorly controlled DM | Age, mean (range): 56 (19–77) y (slightly older in IG3, range 30–76) Race (%): NR Co-morbidities, n (range %): Genitourinary procedures: 57 (12–19%); Essential hypertension: 74 (11–17%); DM: 45 (7–10%); Genitourinary disease: IG1 = 3 (2%) IG2 = 6 (5%) IG3 = 13 (10%) CG = 5 (4%) Depression: 1–2%; Ischemic heart disease: 1–2% Previous ED treatment: NR Smoking status: NR Initial body weight: NR | Concomitant medications: NR Duration of ED (yr) mean (range): 5 (0.5–30) y Underlying disease (diagnosis) (N or % of diseased/ grp): NR Psychogenic ED, n (%): 129 (25) Physiologic ED: n (%): 166 (32) Mixed ED: 219 (42.5) | IG1/IG2/IG3: sildenafil CG: placebo IG1: Dose: 25 mg (IG1); 50 mg (IG2); 100 mg (IG3) Duration: 12 wks Frequency: up to once/d Compliance (%): NR CG: Dose: NA Duration: 12 wks Frequency: up to 1x/day Compliance (%): NR Run In period: 4 wks Wash out period: NA F/u duration (both on and off treatment): mean 85 d | Primary outcome results: IIEF- EF, mean (values approximate extracted from graph): pre 13; Post IG 19 vs. 21 vs. 23 vs. CG 13 IEF- Q3, mean score: IG1= 3.18; IG2= 3.65; IG3= 3.79 vs. CG= 2.17 (IG vs. CG p<0.0001) IIEF- Q4, mean score: IG1= 2.99; IG2= 3.40; IG3= 3.63 vs. CG= 1.96 (IG vs. CG p<0.0001) GEQ, % improved: IG1=67%; IG2=78%; IG3=86%; vs. CG=24% Successful intercourse attempt, mean/mo: range 4.4–5.8 vs. 1.6 Other outcomes assessed: OF, intercourse satisfaction, OS (values NR; IG vs. CG p<0.0001; partner satisfaction Withdrawals/drop-outs/loss to f/u: 6 (2) vs. 1 (<1%) WDAE, n (%): 6 (1.6) vs. 1(0.8) TAE, n (%): 63 (49), 80 (61), 92 (72) vs. 42 (33); most common AE (range % in IG vs. CG)= headache 17–20% vs. 4%; flushing 13–20% vs. 2%; dyspepsia 2–11% vs. 2%; altered vision 0–11% (n 15 pts) vs. 2%; back pain 0–8% vs. 2%; nausea 1–6% vs. 1% SAE: NR (one case of MI in IG2) Ascertainment of outcomes assessed: IIEF, GEQ, partner questions
Montorsi (2000) ^53^ Funding source: NR | N screened = 129 N randomized = 30 (cross-over design) IG/ CG, n = 30 ITT analysis used for primary outcome: No Inclusion: men with ED Exclusion: Depression; hx of sleep disorder; use of drugs affecting quality of sleep; hypogonadism; hx of low serum T, or hyperprolactinemia; MS; SCI; Parkinson's disease; hx of radical pelvic surgery; use of nitrates, complex (≥3 drugs) antihypertensive regimens, or drugs interfering with metabolic pathway of sildenafil; renal or hepatic failure | Age, mean (range): 58 (range 40–68) y Race (%): NR Co-morbidities, n (%): hypertension 12 (40) CAD 10 (33) DM 10 (33) Hyperlipidemia 10 (33) Previous ED treatment: NR Smoking status, n (%): Current smoker 15 (50) Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED, n (%): 8 (27) Physiologic ED, n (%): 22 (73) Mixed ED: NR | IG: sildenafil CG: placebo IG1: Dose: 100 mg Duration: one night Frequency: once Compliance (%): 100 CG: Dose: placebo Duration: one night Frequency: once Compliance (%): 100 Run In period: 1 night adaptation with RigiScan™ attached but turned off Wash out period: none F/u duration: 3 d | Primary outcome results: Number of erectile episodes/ night, mean (SE): 3.8 (0.8) vs. 3.0 (0.5) Duration of erectile episodes, mean (sd): 46.1 (4.4) vs. 33.2 (5.2) min Duration of tip rigidity >60%: 17.5 (1.5) vs. 10.8 (1.7) RAU Tip: 90.5 (8.1) vs. 44.1 (7.8) Base: 101.8 (5.3) vs. 50.2 (4.2) TAU Tip: 55.8 (2.2) vs. 27.2 (1.8) Base: IG1 54.2 (3.1), CG 36.9 (2.2) Other outcomes assessed: None Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE, n (%): 2 (7) vs. 1(3) slight self resolving headache upon awakening SAE: 0 Ascertainment of outcomes assessed: RigiScan™ Rigidity Assessment System
Nurnberg (2003) ^54^ Funding source: Pfizer Inc. | N screened = 117 N randomized = 90 IG, n = 45 CG, n = 45 ITT analysis used for primary outcome: No Inclusion: men 18–55; wit major depressive disorder in remission and tx with antidepressant for more than 12 wk (on stable dose for ≥4 wk); Exclusion: other than antidepressant-associated sexual dysfunction; SCI; uncontrolled psychiatric disorder or DM; proliferative retinopathy; alcohol or substance abuse; sign hematologic, renal or hepatic abnormality; stroke or MI within previous 6 mo; cardiac failure; unstable cardiac condition or arrhythmia; use of nitrates; BP lower than 90/50 or higher than 170/100 mm Hg; hyperprolactinemia, retinitis pigmentosa; investigational drug use within 3 mo; sexual dysfunction tx | Age, mean (sd): 45 (8) y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: Antidepressant 100% Duration of ED: NR; pts with, n (%) ED= 37 (82) vs. 41 (91) Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: sildenafil citrate CG: placebo IG1: Dose: initially 50 mg; could increase to 100 mg Duration: 6 wk Frequency: once/d approximately 1 hr before sexual activity Compliance: NR CG: Dose: NA (titrated as IG) Duration: 6 wk Frequency: as IG Compliance: NR Run In period: None Wash out period: NA F/u duration: 6 wk | Primary outcome results: IIEF, mean score IG vs. CG (baseline IG-CG where different) IIEF, total: pre: 69–40; post 60 vs. 41 IIEF, Q3=Q4: pre: 3; post 4 vs. 3 IIEF, EF, pre: 18–17; post: 27 vs. 17 IIEF, OF: pre 6; post: 8 vs. 6 IIEF, SD: pre: 6; post: 7 vs. 6 IIEF, ICs pre: 6–7; post: 11 vs. 7 IIEF, OS: pre: 4–5; post: 7 vs. 5 ASEX, EF: pre 4; post 3 vs. 4 MGH-SFQ- EF: pre 4; post 3 vs. 5 Other outcomes assessed: see below Withdrawals/drop-outs/loss to f/u: 3 (7) vs. 10 (23) WDAE, n (%): 1 (2) vs. 1 (2), one acute panic and chest pain in IG, one suicidal gesture in CG TAE, %: NR; most common=40.5 vs. 10; AE in headache: 17 (41) vs. 4 (10); dyspepsia 2 (7) vs. 0; flushing 7 (17) vs. 1 (2); visual disturbances 5 (12) vs. 2 (5); nasal congestion 5 (12) vs. 1 (2); palpitations 2 (5) vs. 0; restlessness/anxiety 0 vs. 8 (20); insomnia 4 (10) vs. 2 (5) SAE: 0 Ascertainment of outcomes assessed: Clinical Global Impression Scale -Sexual Function adapted (CGI-SF); Arizona Sexual Experience Scale (ASEX), Massachusetts General Hospital-Sexual Functioning Questionnaire (MGH-SFQ)
O'Leary (2006) ^55^ Funding source: Pfizer Inc. (financial interest and/ or other relationships with Pfizer existed for all authors) | N screened = 326 N randomized = 256 IG, n = 129 CG, n = 127 ITT analysis used for primary outcome: efficacy for all who took at least one dose and presented outcome data; safety for all who took at least one dose Inclusion: men 18 or older with documented ED (score of 21 or less on IIEF) with low self esteem determined by Self-Esteem subscale of the SEAR Exclusion: BP of 90 mmHg or less or 170/110 mmHg or more; sign cardiac dx; use of nitrates, nitric oxide donors, or ritonavir; more than 6 dosed of sildenafil within 6 mo prior to study entry | Age, mean (sd): 56 (12) vs. 55 (13) y Race: White 62%; Black 25%; Asian 2%; Other 11% (16 vs. 6) Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight, mean (sd): 92 (16) vs. 93 (18) kg Other: overall relationship subscale score, mean (sd)=44.4 (33.1) vs. 53.8 (29.8) | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): not specific cause Psychogenic ED, n (%): 18 (14) vs. 15 (12) Physiologic ED, n (%): 61 (48) vs. 62 (50) Mixed ED, n (%): 49 (38) vs. 48 (38) | IG: Sildenafil CG: Placebo IG: Dose: flexible 25–100 mg Duration: 12 wks Frequency: up to once/d, 1 hr prior to sexual activity Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: 2 wks Wash out period: NA F/u duration: 12 wks post dosing | Primary outcome results: IIEF, LS mean change from baseline: EF: 9.3 vs. 3.6, p<0.001 OF: 2.4 vs. 0.8, p<0.001 SD: 1.2 vs. 0.6, p<0.001 IcS: 4.0 vs. 2.2, p<0.001 OS: 2.1 vs. 3.1, p<0.001 Successful sexual attempts, mean change %(95% CI): 52% (44–60%) vs. 19% (11–27%)p<0.0001 GEQ, % (95% CI) more frequent erections allowing satisfactory intercourse: 3.6 (3.3–3.9) vs. 2.4 (2.1–2.7) p<0.0001 Other outcomes assessed: sign correlation between SEAR component scores and IIER-EF domain scores, r range 0.34–0.69, p<0.0001; and other IIEF domain scores Withdrawals/drop-outs/loss to f/u, n (%): 23 (18) vs. 18 (14.4) WDAE, n (%): 0 TAE, n (%): NR; most common %: headache 10 vs. 2; rhinitis 6 vs. 0; vasodilatation 6 vs. 0; dyspepsia 6 vs. 1; chromatopsia, photophobia, dry mouth, and nausea 2 vs. 0; SAE, n (%): 0 vs. 1 death Ascertainment of outcomes assessed: IIEF domains; SEAR
Olsson (2000) ^56^ Funding source: NR | N screened = NR N randomized = 351 IG1, n = 90 IG2, n = 85 IG3, n = 81 CG, n = 95 ITT analysis used for primary outcome: NR Inclusion: men 18–70 y with diagnosis of ED of at least 3 mo duration, who had at least a grade 3–4 (hard enough for penetration-fully rigid) erection at any time during 4 wks before entering the trial or positive response to papaverine (at least 40 mg) or PGE1 (at least 20 mg) Exclusion: Men with ED of organic causes; tx with nitrates, resting hypotension, uncontrolled hypertension, stroke, bleeding disorder, active peptic ulceration, taking anticoagulants, and a hx of a major haematological, renal, hepatic disorders | Age, mean (range): 52 (24–70) y Race (%): NR Co-morbidities: NR Previous ED treatment, n (%): IG: 102 (40) CG: 41 (43) Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 5 (0.2–40) y Underlying disease: NR Psychogenic ED, n (%): 153 (60) vs. 51 (54) Physiologic ED: 2 (1) vs. 0 Mixed ED, n (%): 101 (39) vs. 44 (46) | IG1-3: sildenafil CG: placebo IG1-IG3: Dose: 10 mg (IG1), 25 mg (IG2), 50 mg (IG3) Duration: 4 wks Frequency: once/d Compliance: NR CG: Dose: NR Duration: 4 wks Frequency: once/d Compliance: NR Run In period: NR Wash out period: NR F/u duration: 6 wks | Primary outcome results: IG (1-2-3) vs. CG Mean N of grade 3–4 erections at wk 4, mean n: baseline: 2.1; post tx: 2.8 –3.0 –3.6 vs. 1.8, p < 0.001 (IG vs. CG) GAQ, %: 64 –79 – 88 vs. 38, p < 0.001 Mean Sexual Function Questionnaire (SFQ) scores =improved in IG vs. CG % Partners reporting improved erection: 64 –78 – 83 vs. 39, p < 0.001 Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u, n (%): 7.8 – 8.2% vs. 13.6% vs. 9.5% WDAE, %: 2.2 –4.7– 8.6 vs. 4.2 TAE, %: 24.3 – 58.8 – 45 vs. 15% AE in at least 5% of pts, n (%): headache 12-20-16 (13-24-20) vs. 7 (7); dyspepsia 4-9-5 (4-11-6) vs. 3 (3); flushing 4-7-7 (4-8-9) vs. 0; myalgia 1-3-6 (1-4-7) vs. 1 (1); arthralgia 1-6-0 (1-7-0) vs. 1 (1); flue syndromes 0-5-2 (0-6-3) vs. 2 (2); other (NR) 1-0-2 (1-0-3) vs. 0 SAE, n (%): n=3 (MI, renal cell carcinoma, epileptic crisis) Ascertainment of outcomes assessed: Questionnaire; GAQ; SFQ (15 question, of 14 d diary)
Olsson (2001) ^57^ Funding source: Pfizer | N screened = NR N randomized = 224 IG, n = 136 CC, n = 88 ITT analysis used for primary outcome: yes Inclusion: men 18 or older, with ED of at least 6 mo duration, in a stable relationship for more than 6 mo, clinical diagnosis of stable CVD treated for more than 6 mo with beta blockers and/or ACE inhibitors and/or calcium-channel blockers, written informed consent Exclusion: concomitant tx with nitrates in any form, genital anatomical deformities, any major psychiatric disorder, known hx of alcoholism or substance abuse, SCI, sign CV event (hx of stroke or MI, cardiac failure, unstable angina, life threatening arrhythmia) within 6 mo, major haematological, renal or hepatic abnormalities, poorly controlled DM; BP < 90/50 mmHg or >180/ 110 mmHg | Age, mean (range): 62 (42–77) vs. 62 (41–76) y Race (%): NR Co-morbidities (unrelated to disease): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: no sign differences between grps Duration of ED, mean: 4.6 y Underlying disease, n (%): hypertension: 109 (80) vs.78 (89); Previous MI 25 (18) vs. 18 (20); chronic ischemic heart disease 27 (20) vs. 13 (15); angina 24 (18) vs. 14 (16), Previous coronary bypass 21 (15) vs. 12 (14) Peripheral vascular disease 19 (14) vs. 8 (9) Psychogenic ED: Physiologic ED, %: 63 vs. 60 Mixed ED: 36 vs. 40 | IG: sildenafil CG: placebo IG: Dose: 50 mg with option to titration to 100 or 25 mg based on efficacy and tolerability Duration 12 wks Frequency: up to 1/d Compliance (%): 93% CG: Dose: NA Duration 12 wks Frequency: up to 1/d Compliance (%): 91% Run In period: 4 wks Wash out period: NR F/u duration (both on and off treatment): 12 wks Other: final doses, n (%): 25 mg: 2 (1) vs. 0 50 mg: 51 (38) vs. 9 (10) 100 mg: 83 (61) vs. 79 (90) | Primary outcome results: GEQ, % with improved erection: 71 vs. 24 IIEF, mean (SE): Q3: pre=2; post 3.7 vs. 2.2 Q4: pre=1.5; post 3.3 vs. 1.9 IIEF Q3, and Q4: sign higher in IG than CG (p=0.0001) Other outcomes assessed: partner sexual satisfaction Withdrawals/drop-outs/loss to f/u, (%): 4 vs. 3, due to insufficient clinical response WDAE, n (%): 0 vs. 1 (1) TAE: flushing17 vs. 2; headache 15 vs. 1; dyspepsia 5 vs. 0 SAE: 0 Ascertainment of outcomes assessed: IIEF; GEQ; partner satisfaction questionnaire
Orr (2006) ^58^ Funding source: Pfizer Inc. Israel | N screened = 28 N randomized = 21 (cross over) IG/ CG, n = 21 ITT analysis used for primary outcome: Inclusion: men age 18–60 y, with diagnosis of chronic post traumatic stress disorder (PTSD), and ED (score of less than 50 in IIEF, and les than 20 in IIEF-EF domain), in a stable relationship Exclusion: hx of alcoholism or substance dependence within the last 12 mo; genital or anatomical deformities; SCI; poorly controlled DM; hx of malignant hypertension, resting SBP > 180 mm Hg, hx of stroke or MI within the last 6 mo prior to study entry; predisposing to priapism; any other unstable medical conditions; use of nitrates, or nitric oxide in any form use of sildenafil more than once; tx with T; current use of any ED tx | Age, mean (sd): 44.5 (9.69) y, range 22–55 y Race: NR Co-morbidities, n (%): psychiatric conditions: current major depressive episode 47% (past episodes 29%); dysthyia 7%; current maniac or hyomanid episode 4%; anxiety disorder: social phobia 39%; general anxiety disorder 61%, agoraphobia 61%; obsessive compulsive disorder 4%, psychotic symptoms reported in 38% Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): SSRIs 71%, tri-cyclic antidepressants 21%, other antidepressants 14%, anti-psychotics 25%, mood stabilizer 25%, and benzodiazepine 89% Duration of ED, mean (sd): 19.71 (10.21) Underlying disease, n (%): as in co-morbidities Psychogenic ED, n (%): 100% Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG: Sildenafil CG: Placebo IG1: Dose: 50–100 mg Duration: 4 wks Frequency: one pill 1 hr before sexual activity; total of 6 pills Compliance: NR CG: Dose: NA Duration: 4 wks Frequency: as IG Compliance: NR Run In period: NR Wash out period: no washout included F/u duration: Other: (pts were randomized to 2 grps, 1^st^ grp started with 4 wks placebo, and 2^nd^ grp started with 4 wks sildenafil) | Primary outcome results: IIEF, mean (sd) Total score: baseline 20 (12.32); post 45.19 (15.05) vs. 33.04 (12.99) EF: baseline 7.42 (5.3); post tx 18.57 (7.7) vs. 13.8 (5.3) SD: baseline 4.58 (2.23); post tx 4.95 (2.03) vs. 4.58 (1.8) OF: baseline 4.45 (3.74); post tx 5.59 (2.44) vs. 4.04 (2.15) IcS: baseline 4.39 (3.75); post tx 7.22 (1.92) vs. 6.20 (2.37) OS: baseline 3.37 (1.96); post tx 5.18 (2.55) vs. 4.20 (2.48) Other outcomes assessed: depression, subjective well being and PTSD symptoms score Withdrawals/drop-outs/loss to f/u, n (%): 6/27 (22) in placebo phase; 1/23 (4.3%) in sildenafil phase WDAE, n (%): NR TAE, n (%): NR, AEs included heartburn, decrease in appetite, constipation, diarrhea, nausea, vision blur, tinnitus, dizziness, headache, tiredness, backache, stomach ache, chest pain, hot flushes, rash, palpitation, sweating; no sign.between grps SAE, n (%): NR Ascertainment of outcomes assessed: IIEF domains; depression, subjective well being by SAS and ABS); PTSD symptom scores
Padam-Nathan (1998) ^59^ Funding source: Pfizer | N screened = NR N randomized = IG, n = 163 CG, n = 166 ITT analysis used for primary outcome: yes (last observation carried forward) Inclusion: men 18 or older, with ED of more than 6 mo, ED (ED aetiology determined at screening by medical hx, penile tumescence test, IC injection test, endocrine testing, and penile duplex ultrasonography) Exclusion: penile anatomical defects; SCI; other sexual disorders; low T; poorly controlled DM or untreated proliferative diabetic retinopathy; psychiatric dx; active peptic ulcer dx; hx of major haematological, renal, or hepatic abnormalities; recent hx of CV dx, stroke, or MI, or alcoholism; or substance abuse; tx with nitrates, androgens or trazodone | Age, mean (range): 60 (26–79) vs. 59 (31–81) y Race: NR Co-morbidities, (%): hypertension 24 vs. 28; Hyperlipidemia 15 vs. 15; ischemic heart dx 15 vs. 8; DM (any type) 8 vs. 11; depression 3 vs. 3; radical prostatectomy 9 vs. 11 Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED, mean (range): 5 (0.5–26) y Underlying disease, n (%): NR Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG: Sildenafil CG: Placebo IG: Dose: 50 mg (titrated to 100 mg, or 25 mg at 2 wks based on effecacy and tolerability); total 32 doses Duration: 12 wks (median=87 d) Frequency: up to one/d (approximately 1 hr before sexual activity) Compliance: NR CG: Dose: NA/ total of 29 doses Duration: 12 wks (median = 86 d) Frequency: as IG Compliance: NR Run In period: 4 wks no tx Wash out period: NR F/u duration: 12 wks Other: 23% of pts were on 50 mg; 74% on 100 mg at the end | Primary outcome results: GEQ, (% yes): 101/136 (74%) vs. 23/118 (16%), p<0.0001 Erection sufficient for intercourse, n (%): 94/137 (69) vs. 32/138 (23) Maintaining erection after penetration, n (%): 85/137 (62) vs. 22/138 (16) Maintaining erection on most occasions, n (%): 81/137 (59) vs. 21/138 (15) Successful intercourse, (%): 65% vs. 20%, p < 0.001 Frequency of successful intercourse attempts (n/mo): 5.9 vs. 1.5, p <0.0001 Other outcomes assessed: partner assessment of sexual performance Withdrawals/drop-outs/loss to f/u, n (%): 9 (8) vs. 13 (6) WDAE, n (%): 1 (<1) vs. 2 (1) TAE, n (%): AE in at least 5% of pts= headache 30 (18) vs. 6 (4); flushing 30 (18) vs. 1 (1); dyspepsia 9 (6) vs. 4 (2); abnormal vision (▴ sensitivity or light or blurred vision) NR (3) vs. NR (1) SAE, n (%): NR Ascertainment of outcomes assessed: GEQ; pts log (sexual stimulation, and successful intercourse); optional two item partner questionnaire; IIEF (15 item version); AE by examiner
Padma-Nathan (2003) ^60^ Funding source: Pfizer Inc. | N screened = NR N randomized = 228 IG, n = 115 CG, n = 113 ITT analysis used for primary outcome: No Inclusion: pts 18 or older with clinically documented ED at least 6 mo duration who had previously responded successfully to sildenafil treated minimum. of 2 mo, in a stable 100-mg sildenafil dose, established single-partner relationship; had to discontinue all medications for ED Exclusion: tx with nitrates or nitric oxide donors and those with hypotension (BP less than 90/50 mmHg), hypertension (PB more than 170/110 mmHg), MI, unstable angina, stroke, or symptomatic or clinically sign cardiac abnormalities in the past 3 mo | Age, mean (sd): 61(10) vs. 59(11) Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Initial body weight: NR | Concomitant medications: NR Duration of ED (yr, SD): 6.8(4.6) vs.7.2 (5.4) Underlying disease: NR Psychogenic ED n (%): 3 (3) vs. 4 (4) Organic ED, n (%): IG 61 (53) vs. 66 (58) Mixed ED, n (%): 36 (31) vs. 29 (26) | IG: sildenafil CG: placebo IG: Dose: 100 mg Duration: 4 wks Frequency: up to once/d; as need Compliance: NR CG: Dose: NA Duration: 4 wks Frequency: as IG Compliance: NR Run In period: NR Wash out period: 2 wks F/u duration: 4 wks | Primary outcome results: IIEF: IG sign higher scores vs. CG for all domains p<0.001 (results provided in Figure 2) Sexual activity event log, mean time to onset of erection (min): 36.3 vs. 140.7 min. (sign, p<0.0001) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 4 (3.5) vs. 5 (4.4) WDAE: 2 (2) vs. 0 TAE: 41 vs. 18 in 29 (25%) vs. 15 (13%) of pts, most common AE, %: headache 6 vs.0; flushing 3.5 vs.0.9; respiratory tract infection 4.3 vs. 4.4; sinusitis 0 vs. 5 SAE: NR Ascertainment of outcomes assessed: Sexual activity event log: recorded at home time duration of sexual activity using a stopwatch. Other question: whether erection lasted long enough for successful intercourse. IIEF: questionnaire.
Padma-Nathan, (1999) ^32^ Funding source: NR | N screened = NR N randomized = 532 IG, n = 316 CG, n = 216 ITT analysis used for primary outcome: No Inclusion: ED Exclusion: penile anatomical deformities, hyperprolactinaemia or testosterone deficiency, stroke, MI, or sign. CVD in the previous 6 mo, poorly controlled DM or major psychiatric disorder, untreated proliferative diabetic retinopathy, major haematological, renal or hepatic abnormalities, active peptic ulcer dx, retinitis pigmentosa, concomitant tx with nitrates, nitric oxide donors, androgens or trazodone, hx of alcoholism or substance abuse | Age, mean (range): 58 (20–87) Race: NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean: 3.2 y Underlying disease (%): NR Psychogenic ED (%): 9 Organic ED (%): 77 Mixed ED (%): 13 | IG: sildenafil CG: placebo IG1: Dose: 25, 50 or 100 mg Duration: 6 mo Frequency: as need before sexual activity Compliance: NR CG: Dose: placebo Duration: 6 mo Frequency: as need before sexual Compliance: NR Run In period: 4 wks Wash out period: NR F/u duration: 6 mo | Primary outcome results: Erections hard enough for sexual intercourse, mean %: 72 (25mg), 80 (50 mg), 85 (100mg) vs. CG 50 (p < 0.001) Number of erections, mean/mo: Grade 3= 2.1(25 mg), 2.4 (50 mg), 3.1 (100 mg) vs. CG 2.4 (p < 0.001); Grade 4=2.2 (25 mg), 4.2 (50 mg), 3.4 (100 mg) vs. CG 0.7 (p < 0.001) Successful intercourse (%, grade 3,4): grade 3 = 80 vs. NR grade 4 = 94 vs. NR Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: NR WDAE, n (%): 25 mg =1(1), 50 mg= 1 (1), 100 mg =2 (2) vs. CG= 1 (4) TAE, n (%): headache 25 mg =14(14), 50 mg= 23 (21), 100 mg= 32(30) vs. CG= 14 (6); flushing 25 mg= 13 (13), 50 mg= 29 (27), 100 mg 21 (20) vs. CG= 3 (1); Dyspepsia 25 mg= 3 (3), 50 mg= 12 (11), 100 mg= 17(16) vs. CG= 3 (1) Abnormal vision, 25 mg= 2(2), 50 mg =6 (6), 100 mg =10(9), CG= 1 (1) Rhinitis, 25 mg= 1(10), 50 mg =3 (3), 100 mg= 12(11), CG= 4 (2) SAE: NR Ascertainment of outcomes assessed: event log (4-point erection hardness scale and successful sexual intercourse attempts)
Palmer (1999) ^61^ Funding source: Pfizer Inc. | N screened = NR N randomized = 8 (crossover study) ITT analysis used for primary outcome: No IG/CG, n = 8 Inclusion: men with ED and spina bifida Exclusion: NR | Age, range: 19–35 y Race (%): NR Co-morbidities (unrelated to disease): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: sildenafil CG: placebo IGa/ IGb: Dose: a=25 mg; b=50 mg (one set for each dose; 5 tablets/ set) Duration: NR Frequency: 1/d Compliance (%): 100% CGa/ CGb: Dose: NA (two sets of tablets) Duration: NR Frequency: 1/d Compliance (%): 100% Run In period: NR Wash out period: NR F/u duration: NR | Primary outcome results: Duration of erection, mean Baseline: 8.9 min Low dose: 17.9 vs. 10.4 min High dose: 25.6 vs. 13.5 min (improvement of 101% and 188% for IG a and b respectively) IIEF, high dose; low dose IG vs. CG mean score: Q1 baseline 2.1; post: 3.3; 4.4 vs. 2.5 (improvement of 57% and 110% for IG grps) Q15 baseline 2.3; post 3.0; 3.8 vs. 2.6 (improvement of 30% and 65% for IGa and b respectively) Erectile score: baseline 3.4; post 5.8, 6.9 vs. 3.7 (improvement of 71% and 103% for IG a and b respectively) Other outcomes assessed: None Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: 0 SAE: 0 Ascertainment of outcomes assessed: IIEF
Palmer (2000) ^62^ Funding source: Pfizer, Inc | N screened = 17 N randomized = 17 (cross over) IG/CG, n = 17 ITT analysis used for primary outcome: No Inclusion: men 18–35 with diagnosed spina bifida, and ED, medical clearance from primary care physician Exclusion: abnormal haematological evaluation, medical contraindications | Age, range: 19–35 y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): NR Underlying disease: Spina Bifida 100% Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1/2: sildenafil- oral CG: placebo- oral IG1/ IG2: Dose: 25 mg (IG1), 50 mg (IG2) Duration: NR Frequency: up to once/d, one hr before sexual activity; pts were given 4 sets of tablets (sildenafil 25 mg, 50 mg and two identical looking placebo tablet), 5 tablets/ set in a random order) Compliance: 88% CG1: Dose: NA Duration: NR Frequency: as IG Compliance: 88% Run In period: NR Wash out period: NR F/u duration: NR | Primary outcome results: IIEF, mean score (values approximate from figure): Q3- baseline= <2.5 vs. <3; 12 wks: <3 vs. >3.5, p=0.001 (improvement in 35.7% vs. 19.9% of pts) Q4- baseline: <2; 12 wks: <2.5 vs. >3, p=0.001 (improvement in 68.4% vs. 26.5% of pts) Number of successful intercourse attempts (event log), %- baseline: 20; 12 wks 40 vs. >65, p=0.001 (improvement in 63% vs. 33% of pts) EF domain- baseline: <14; 12 wks: 15 vs. 20, p=0.001 GEQ, % improved: 66.6 vs. 28.6 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 4 (24) WDAE: 0 TAE, n (%): 5 (33) only with 25 mg including dyspepsia 1 (7); nausea 1 (7); headache, flushing and nasal congestion 1(7); urinary tract infection 1 (7), and haematological changes 1 (7) SAE: 0 Ascertainment of outcomes assessed: IIEF, Q1 and 15, patient ratings of erection
Perimenis (2004) ^63^ Funding source: NR | N screened = NR N randomized = 30 IG1, n = 15 IG2, n = 15 CG, n = NA ITT analysis used for primary outcome: Yes Inclusion: Men with clinically diagnosed ED and obstructive sleep apnea syndrome (OSAS) Exclusion: deformity in external genitals, taking nitrates, being treated for ED, hormonal deficiency, had not had a stable relationship for at least 6 mo | Age, mean (sd): 55.7 (3.6) vs. 56.4 (3.3) Race (%): NR Co-morbidities: DM (NR), atherosclerosis (NR), CAD (NR), hypertension (NR) % Pts with => 1 disease: n=11 (73%), in each arm Previous ED treatment: NR Smoking status, n (%): smokers 23 (77) Body weight: most pts were overweight | Concomitant medications: NR Duration of ED: 16.7 (7.6) vs. 15.7 (6.1) mo Underlying disease: OSAS (100%) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: Continuous Positive Air Pressure (CPAP) IG2: Sildenafil IG1: Dose: NA Duration: 12 wks Frequency: nightly Compliance (%): NR IG2: Dose: 100 mg Duration: 12 wks Frequency: NR Compliance (%): NR Run In period: NR Wash out period: NR F/u duration: 12 wks | Primary outcome results: Mean (sd) scores IG1 vs. IG2: IIEF total: pre=21.7 vs. 23.3; post = 27.3 (8.6) vs. 37.7 (10.5), p = 0.0025 IIEF-EF: pre=7 vs. 8; post 9 (3) vs. 13 (4) IIEF-OF: pre=3; post: 3 (1.6) vs. 5.5 (1.9) IIEF-SD: pre=7; post: 7 (1.4) vs. 7.7 (0.8) IIEF ICs: pre=3.3 vs. 3.7; post: 4.6 (1.7) vs. 6.4 (2) IIEF-OS: pre=2; post 2.9 (1.6) vs. 4.5 (2.3) pts satisfied with the treatment, n/N (%) = 3/15 (20) vs. 8/15 (53.3), p = 0.13 Successful attempts for intercourse, n/N (%) = 33/138 (23.9) vs. 97/180 (53.9), p = 0.001 Mean N of attempts per patient = 9.2 vs. 12, p = 0.005 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: None WDAE: 0 TAE: NR SAE: 0 Ascertainment of outcomes assessed: RigiScan, IIEF; pts diary questionnaire
Perimenis (2007) ^64^ Funding source: NR | N screened = N randomized = 40 IG1, n = 20 IG2, n = 20 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: men with ED and sleep apnea (complete cessation of airflow for at least 10 s and hypopnea as the reduction in airflow by at least 50% for 10 s or more) Exclusion: genital deformity, use of nitrates; on tx with ED; hormonal deficiency, not in a stable relationship for at least 6 mo | Age, mean (range): 55.3 (42–64) vs. 55.5 (48–62) y Race: NR Co-morbidities, n (%): NR Previous ED treatment: None Smoking status: NR Body weight: NR Other: respiratory disturbance index (RDI) 9.9 (6–24) vs. 8.9 (6–25) | Concomitant medications, n (%): NR Duration of ED: 17.5 (6–36) vs. 18.7 (8–36) mo Underlying disease, n (%): NR Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG1: Sildenafil IG2: Continous Positive Airway Pressure (CPAP) CG: IG1: Dose: 100 mg on demand, 1 hr prior to sexual activity Duration: 12 wks Frequency: once/d Compliance: NR IG2: Dose: NA Duration: 12 wks Frequency: during night time sleep Compliance: NR Run In period: 4 wks Wash out period: NA F/u duration: 12 wks (every 4 wks) | Primary outcome results: Rate of successful intercourse attempts, per pts: 128/249 (51.4%) vs. 51/193 (26.9%) IIEF-EF, mean (sd): Baseline: 7.8 (1.2) vs. 7 (1.9) Post tx: 14.3 (5.0) vs. 10.8 (4.4), p = 0.025 Other outcomes assessed: satisfaction with tx (better with sildenafil, 50% vs. 25%, p=0.007) Withdrawals/drop-outs/loss to f/u, n (%): 0 WDAE, n (%): 0 TAE, n (%): NR SAE, n (%): 0 Ascertainment of outcomes assessed: pts diary; IIEF, EDITS
Pickering (2004) ^65^ Funding source: Pfizer | N screened = 670 N randomized = 568 IG, n = 281 CG, n = 287 ITT analysis used for primary outcome: yes Inclusion: men 18 or older with ED and hx of arterial hypertension treated with 2 or more different antihypertensive drugs, with stable dose for at least 4 wks; in stable relationship Exclusion: hypotension or uncontrolled hypertension, sign CV dx in previous 6 mo; current use of nitrates; past tx with sildenafil | Age, mean (sd): 59 (8) vs. 59 (9) Race: NR Co-morbidities: None Previous ED treatment: None Smoking status: NR Body weight: NR | Concomitant medications: None Duration of ED, mean (sd): 4.6 (4.1) vs. 4.5 (4.6) y Underlying disease: Arterial hypertension Psychogenic ED, n (%): 23 (8.2) vs. 24 (8.5) Physiologic ED, (%): 145 (52) vs. 142 (50.2) Mixed ED, n (%): 111 (39.8) vs. 117 (41.3) | IG: Sildenafil CG: Placebo IG: Dose: 50mg (after2 wks adjusted to 25 or 100 mg) Duration: 6 wks Frequency: before sexual intercourse Compliance (%): (94) CG: Dose: 1 tablet Duration: 6 wks Frequency: before sexual intercourse Compliance (%): (95) Run In period: 2 wks screening period Wash out period: None F/u duration (on and off treatment): Trial followed up by 6 wks open label phase where all participants received Sildenafil. | Primary outcome results: IIEF mean (sd) IG1 vs. CG Q3: pre= 3.6 (0.1) vs. 2.7 (0.1) Q4 (penetration): 3.6 (0.1) vs. 2.5 (0.1) GEA-Q1, % improved: 71 vs. 18 1: Improved erections: (71) vs. (18) GEA-Q2, %: 69 vs. 20 Intercourse success rate, %: 62 vs. 26 Other outcomes assessed: EDITS: Patients who took sildenafil score higher mean scores on EDITS Withdrawals/drop-outs/loss to f/u, n (%): 7 (2.5) vs. 5 (2) WDAE, n (%): 4 (1.4) vs. 4 (1.4) TAE, n (%): 111 (39.9) vs. 73 (26) including headache 28 (10.1) vs. 10 (3.6); flushing 17 (6.1) vs. 1 (0.4); dyspepsia 15 (5.4) vs. 3 (1.1); dizziness 11 (4) vs. 1 (0.4); nasal congestion 7 (20.5) vs. 1 (0.4); abnormal vision 7 (2.5) vs. 0 SAE: 2 (0.7) vs. 2 (0.7); including one due to MVA in CG Ascertainment of outcomes assessed: IIEF-Q3, and 4; GEA-Q1 and 2; pts event log
Price (1998) ^66^ Funding source: Pfizer | N screened = NR N randomized = 21 (3 way cross over; two periods) IG1/IG2/CG, n = 21 ITT analysis used for primary outcome: NR Inclusion: men 18–70 y with hx of DM type 1 or 2, for 5 y or more, ED of at least 6 mo (ED definition and diagnosis is described) Exclusion: sign ischemic heart dx or peripheral vascular dx, tx with antidepressants/tranquillizer, nitrates, anticoagulants, or salicylates in last 2 wks prior to study, hx of bleeding dx, severe untreated proliferative diabetic retinopathy, no ED tx in past 2 wks | Age, mean (range): 51 (42–65) y Race: NR Co-morbidities: Blood glucose (or HbA1C): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, median (range): 3 (1–14) y Underlying disease: 100% DM, with mean duration of 11 (range 3–32) y; evidence of peripheral or autonomic neuropathy n=6 (28%) Psychogenic ED: NR Physiologic ED: 100% Mixed ED: NR | Phase I IG: single dose sildenafil + 90 min visual sexual stimualtion (VS) CG: placebo Phase II IG: sildenafil CG: placebo IG phase I: Dose: 25 mg (IG1), 50 mg (IG2) Duration: NA Frequency: single dose Compliance: NR IG phase II: Dose: 25 mg (IG1), 50 mg (IG2) Duration: 10 d Frequency: once/d Compliance: NR CG phase I & phase II: Dose: NA Duration: as IG in respective phase Frequency: as IG Compliance: NR Run In period: 2 wks Wash out period: NR F/u duration: immediately post tx | Primary outcome results: Phase I, duration of erection with > 60% rigidity, mean (95% CI): Base: 5 (1.9–12.4) vs. 10.1 (4.2–23.1) vs. 2.8 (0.7–8.4) min Tip: 1.2 (0.2–3.8) vs. 2.2 (0.7–6) vs. 0.4 (-0.2–2.1) min Phase II (home study) N of erection sufficient for intercourse (grade 3 or 4), mean (95% CI): 1.3 (0.9–1.8) vs. 1.6 (1.1 –2.1) vs. 0.6 (0.4–0.9) % of pts with improved erection, n (%): 10 (50) in 25 mg vs. 2 (10) in placebo 11 (52%) in 50 mg vs. 2 (10) in placebo Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE: NR; tx related AEs= 8 vs. 8 vs. 3 including headache 4 vs. 0, myalgia 3 vs. 2, nausea 2 vs. 1, and dyspepsia 5 vs. 0 SAE: 1 (4.7) vs. 0; pneumococcal pneumonia with 25 mg dose Ascertainment of outcomes assessed: RigiScan (phase I); self report on grading system (phase II)
Randell (1999) ^67^ Funding source: study medications by Pfizer (author has served as paid consultant for Pfizer) | N screened = NR N randomized = 268 IG, n = 136 CG, n = 132 ITT analysis used for primary outcome: yes Inclusion: men 18 or older, medically documented ED for at least 6 mo, managed and stable DM (type 1at least 5 y, type 2 at least 2 y); in a stable relationship for at least 6 mo Exclusion: penile anatomical deformities, primary diagnosis of sexual disorder other than ED; sign psychiatric dx; SCI, hx of major haematological, renal, or hepatic abnormalities; stroke or MI, in past 6 mo; active peptic ulcer; hypo/hypertension, diabetic retinopathy or severe autonomic neuropathy; hx of ketoacidosis in last 3 y; tx with nitrates or androgens | Age, mean (range): 57 (27–79) y Race: NR Co-morbidities, n (%): hypertension 139 (51); ischemic heart dx 70 (26) Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): antihypertensive agents 141 (53); diuretics 33 (12); beta blockers 19 (7); antidepressant agents 13 (5) Duration of ED: NR Underlying disease, n (%): DM type I= 50 (18); type II = 136 (50); Psychogenic ED: NR Physiologic ED, (%): 256 (96) Mixed ED, n (%): 12 (4) | IG: Sildenafil CG: Placebo IG: Dose: 50 mg (titrated up to 100, or down to 25 mg according to pts tolerability and efficacy) Duration: 12 wks Frequency: up to once/d (1 hr prior to sexual activity) Compliance: NR CG: Dose: NA Duration: 12 wks Frequency: as IG Compliance: NR Run In period: 4 wk (no tx) Wash out period: NA F/u duration: 12 wks Other: pts receiving sildenafil 100 mg (high for placebo)= 126 (93%) vs. 127 (96%); 50 mg (medium) = 10 (7%) vs. 5 (4%); 25 mg (low) = 0 vs. 0 | Primary outcome results: IIEF, Q1, 2, 3, 4 (baseline = 2), at 12 wk, mean (SE) for individual questions: 3 (0.2) vs. 2 (0.2); increase of 78% vs. 25%, P<0.001 IIEF, EF (Q5, 15): pre=1, post: individual questions, mean (SE): 3 (0.2) vs. 2 (0.2) Pts with at least 1 successful attempt at sexual intercourse: 61 (71/117) vs. 22 (25/114), p<0.001 Other outcomes assessed: sexual satisfaction and OF; IIEF 11 & 12 (no change); efficacy variables for subgrp of DM pts Withdrawals/drop-outs/loss to f/u, n (%): 16 (6); IG 11 (8), vs. CG 5 (4) WDAE: 1 (<1) vs. 1 (<1); no detail TAE: AE in at least 3% of pts= 22 (16) vs. 5 (5); including: headache 15 (11) vs. 2 (2); dyspepsia 12 (9) vs. 0; respiratory tract disorder 8 (6) vs. 2 (2); CV 4 (3) vs. 6 (5); flushing 5 (4) vs. 0; abnormal vision 5 (4) vs. 1 (1) SAE: NR Ascertainment of outcomes assessed: IIEF Q1, 2, 5–15 self report ability to achieve and maintain erection for sexual intercourse
Safarinejad (2004) ^68^ Funding source: NR | N screened = 373 N randomized = 282 IG, n = 144 CG, n = 138 ITT analysis used for primary outcome: Yes Inclusion: pts 18 or older, with ED (NIH consensus), and DM longer than 6 mo; in a heterosexual stable relationship for at least 6 mo, and no tx for ED 4 wks prior to trial Exclusion: anatomaical defects, another sexual disorder, major haematological, renal, hepatic, uncontrolled psychiatric disorder, tx with nitrates, androgens, CAD, hx of MI or stroke, peptic ulcer dx, poorly controlled DM, hx of drug/alcohol abuse, SCI, hypotension (resting < 90/50 mmHg) or hypertension (resting > 100 mmHg), proliferative retinopathy or autonomic neuropathy and hx of ketoacidosis | Age, mean (range): 46 (36–68) y Race (%): NR Co-morbidities: NR Previous ED treatment: NR (none in 4 wks prior to trial) Smoking status: NR Body weight: NR Other: HbA1C, % = < 0.12 | Concomitant medications, %: ACE inhibitors without diuretics 22; ACE inhibitors with diuretics 22.5, diuretics 12; β-blockers 4 Duration of ED (yr): 3.6 (2.5–12) Underlying disease, %: DM type I =17; type II= 83 Psychogenic ED: None Physiologic ED: 96% Mixed ED: 4% | IG: Sildenafil CG: Placebo IG: Dose: 100 mg Duration: 16 wks Frequency: once/d Compliance: NR CG: Dose: NR Duration: 16 wks Frequency: as IG Compliance: NR Run In period: NR Wash out period: NR F/u duration: 16 wks | Primary outcome results: IIEF-Q3, mean (SE): pre: 1.8 (0.2); post: 2.8 (0.2) vs. 2.2 (0.2), p < 0.002 (vs. baseline) IIEF-Q4, mean (SE): pre 1.7 (0.2); post: 2.9 (0.2) vs. 2.0 (0.2), p < 0.002 (vs. baseline) GEQ, n (%) with positive response: 68 (51) vs. 14 (11), p < 0.003 Other outcomes assessed: Mean scores of IIEF 1,2,5–10,13–15 (improved with sildenafil, p <0.05) Withdrawals/drop-outs/loss to f/u, n (%): 10 (7) vs. 10 (7) WDAE, n (%): 8 (6) vs. 0 TAE: NR; most common AEs=22 vs. 1.4 (p < 0.001); AE included headache 29 (20) vs. 3 (2), flushing 27 (19) vs. 0; dyspnea 13 (9) vs. 3 (2); rhinitis 9 (6) vs. 0; CV events 10 (7) vs. 0; prolonged erection 1 (1.4) SAE: NR [CV events in sildenafil grp = four chest pain (two MI), two heart failures and four hypertensions] Ascertainment of outcomes assessed: Questionnaire
Safarinejad (2006) ^69^ Funding source: not sponsored | N screened = 430 (486 entered a preliminary phase to emphasize the timing and instruction of sildenafil; responders were excluded) N randomized = 402 IG1, n = 205 IG2, n = 197 ITT analysis used for primary outcome: yes Inclusion: men 18 y or older with ED; in a stable relationship, non-responders to sildenafil, and no tx of ED within the last 4 wks prior to entering the study Exclusion: penile anatomical defects, primary dx of another sexual disorder, use of psychotropic and antidepressant medications, poorly controlled DM, uncontrolled congestive or ischemic heart dx or renal or liver impairment, hx of alcohol or drug abuse, SCI, hx of prostate cancer, neurological dx causing ED | Age, mean (range): 41.5 (21–59) y Race: NR Co-morbidities, n (%): DM 44 (12); hypercholesterolemia 91 (24.6); hypertension 87 (23.5); Ischemic heart dx 52 (14) Previous ED treatment: NR Smoking status: smokers 192 (52) Body weight: NR | Concomitant medications, n (%): Duration of ED, mean (range): 2.8 (1.9-7) y Underlying disease, n (%): NS between grps: arteriogenic132 (32.8); mixed vasculogenic 105 (26); veno-occulsive dysfunction 97 (24); corporeal fibrosis 8 (2) Psychogenic ED, n (%): 15 (7.3) vs. 13 (6.6) Physiologic ED, n (%): 374 (93) Mixed ED: NR | IG1: Sildenafil + Cabergoline IG2: Sildenafil + placebo IG1: Dose: sildenafil= 50 ▴ rapidly to 100 if not results were observed with the attempt; cabergoline= 0.5 mg ▴ by 0.25 biwkly up to 1 mg/wk Duration: 6 mo Frequency: sildenafil: pkg instruciton up to 1/d; cabergoline: wkly Compliance: NR IG2: Dose: sildenafil as IG1+ placebo Duration: 6 mo Frequency: as cabergoline Compliance: NR Run In period: NR Wash out period: NR F/u duration: 6 mo | Primary outcome results: IIEF, LS mean (SE) scores: Q3: baseline 1.8 (0.2); post tx 3.3 (0.2) vs. 2 (0.2) Q4: baseline 1.7 (0.2); post tx 3.7 (0.2) vs. 2 (0.2) All other IIEF individual questions sign improved with cabergoline, p=0.04 IIEF- IcS domain mean score: baseline 10 vs. 11; post tx 15 vs. 10 Successful intercourse attempts (% with at least one success): 36% vs. 6% Other outcomes assessed: IVELT sign difference between tx grps (p=0.001) Withdrawals/drop-outs/loss to f/u, n (%): 19 (9.3) vs. 13 (6.6) WDAE, n (%): 12 (5.9) vs. 2 (1) TAE, n (%): pts with AE 25 (12.2) vs. 4 (2) including nausea, headache, dizziness, somnolence SAE, n (%): NR Ascertainment of outcomes assessed: IIEF, Intra-vaginal ejaculatory latency time (IVELT) evaluation, serum T, and PRL levels
Seibel (2002) ^70^ Funding source: NR | N screened = 226 N randomized = 48 IG, n = 24 CG, n = 24 ITT analysis used for primary outcome: NR Inclusion: men aged <70 yr; on hemodialysis for ≥6 mo; in stable relationship with female partner Exclusion: penile anatomic abnormality; cirrhosis; diabetes; angina; severe anemia; nitrate treatment; hx of recent (within previous 6 mo) stroke or myocardial infarction; illiteracy; current ED treatment | Age, mean (sd): 49 (10) vs. 46 (9) Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Initial body weight: NR Other: Duration of hemodialysis, mean (sd): 42 (31) vs. 36 (26) mo | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: Nr Mixed ED: NR Other: ED severity, n: Severe 2 vs. 3 Moderate 11 vs. 10 Mild-moderate 5 vs. 6 Mild 2 vs. 2 | IG: sildenafil orally CG: placebo orally IG: Dose: 50 mg Duration: 1 mo Frequency: 1 dose 1 hr before sexual intercourse; max. 1/d; no drug when on hemodialysis Compliance (%): NR CG: Dose: placebo Duration: 1 mo Frequency: as IG Compliance (%): NR Run In period: NR Wash out period: NA F/u duration: 1 mo | Primary outcome results: IIEF -change from baseline (mean): Q3: 1.2 vs. 0.05 Q4: 1.4 vs. no change EF: 7.0 vs. 0.2 OF: 1.7 vs. 0.4 SD: 0.5 vs. 0.4 ICs: 2.6 vs. 0.7 OS: 2.3 vs. 0.6 Other outcomes assessed: change in severity of ED; Withdrawals/drop-outs/loss to f/u: 4 (17) vs. 3 (13) WDAE: 0 TAW: 5 vs. 3; pts with AE =3 (13) vs. 3 (13); including headaches, facial flushing, dyspepsia vs. headaches and facial flushing SAE: 2 deaths in CG (neither associated with placebo ingestion or sexual intercourse) Ascertainment of outcomes assessed: IIEF
Seidman (2001) ^71^ ^72^ Funding source: Pfizer Inc. | N screened = 300 N randomized = 152 IG, n = 74 CG, n = 78 ITT analysis used for primary outcome: yes Inclusion: men 18 or older, with ED of at least 6 mo in duration, and in stable heterosexual relationship for > 6 mo, ED, DSM-IV (not defined) criteria for depressive disorder, 24-item Hamilton depression scale score ≥ 12 at both screening interviews. Exclusion: other psychiatric disorder, substance abuse or dependence, current use of nitrates or antidepressant medication, abnormal serum hormone levels, hx of major hematologic renal or hepatic abnormalities, poorly controlled diabetes, retinitis pigmentosa, spinal cord injury, serious CV dx | Age, mean (sd): 57 (10) vs. 55 (12); range 25–81 y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: baseline depression scores: Beck Depression inventory, mean, (sd): 15 (8) vs. 16 (7) | Concomitant medications: NR Duration of ED (yr (sd): 6 (6) vs. 5 (5) range 0.3–33 y Underlying disease: 1 radical prostatectomy Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: oral sildenafil CG: oral placebo IG: Dose: 50 mg with option to titrate up to 100 mg or down to 25 mg Duration: 12 wks Frequency: once/d Compliance (%): 87.8 CG: Dose: NA Duration: 12 wks Frequency: once/d Compliance (%): 76.9 Run In period: NR Wash out period: NR F/u duration: 12 wks Other: pts in dose grps at 12 wks, n (%): 100 mg: 57 (79) 50 mg: 14 (19) 25 mg: 1 () in IG, 73 (97) in CG. | Primary outcome results: Overall IIEF mean (SE) score: 23 (1.5) vs. 12 (1), p < 0.001 Ability to achieve erection; mean (SE): 4 (0.3) vs. 2 (0.2) Maintaining erection: 4 (0.3) vs.2 (0.2) CGI, improved erections, n (%): 60/66 (91) vs. 8/70 (11) Successful sexual intercourse, n (%): 59/66 (89) vs. 9/70 (13) % Pts responders = 73% vs. 14% Other outcomes assessed: Depressive symptoms, quality of life Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE, n (%): 43 (58) vs. 7 (9); AE in at least 5% of pts: headache 15 (20) vs. 5 (6); dyspepsia 11 (15) vs. 0; flushing 11 (15) vs. 1 (1); abnormal vision 6 (8) vs. 1 (1) SAE: NR Ascertainment of outcomes assessed: Clinical Global Impression Improvement (CGI); Self report questionnaires, Hamilton depression scale, Clinical Global Improvement scale, Beck Depression Inventory, IIEF, Life Satisfaction Checklist, physical exam
Shabsigh (1999) ^73^ Funding source: NR | N screened = NR N randomized = 329 IG, n = 163 CG, n =166 ITT analysis used for primary outcome: NR Inclusion: men with ED of 6 mo or longer Exclusion: NR | Age, mean: NR Race: NR Co-morbidities: NR Previous ED treatment: NR, all had tx for at least 6 mo prior to trial Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease (%): ED 100 Psychogenic ED (%): 15 Organic ED (%): 59 Mixed ED (%): 26 | IG: sildenafil CG: placebo IG: Dose: 5 mg Duration: 12 wks Frequency: 1 hr before sexual activity Compliance: NR CG: Dose: placebo 5 mg Duration: 12 wks Frequency: 1 hr before sexual activity Compliance: NR Run In period: 2 wks (efficacy and toleration) Wash out period: NR F/u duration: 12 wk | Primary outcome results: IIEF, mean score: Q3: 3.9 vs. 2.3 (p < 0.001) Q4: 3.6 vs. 1.8 (p < 0.001) Other outcomes assessed: NA; aetiology of ED had no sign effect on outcome Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: IIEF question 3 and 4 (/5)
Sharma (2006) ^74^ Funding source: Zydus Cadila | N screened = NR N randomized = 32 (randomized cross over) IG/ CG, n = 32 ITT analysis used for primary outcome: NR Inclusion: men 18 or older and medically documented ED, who were renal transplant recipients with stable graft function in the last 6 mo; also in a stable relationship Exclusion: penile anatomic deformities, hx of recent stroke, MI, in last 6 mo, proliferative diabetic retinopathy, sever autonomic neuropathy, regular tx with nitrates/ androgens; SCI | Age, mean (sd): 40 (8) Race: NR Co-morbidities, n (%): chronic glomerulonephritis 14 (43); chronic interstitial nephritis 8 (25); diabetic nephropathy 7 (22); other basic diseases 3 (9.4) Previous ED treatment: NR Smoking status: NR Body weight: NR Other: blood levels of hemoglobin, nitrogen, creatinine was reported | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): renal allograft Psychogenic ED, n (%): NR Physiologic ED, n (%): 100% Mixed ED, n (%): NR | IG: Sildenafil CG: Placebo IG: Dose: 50 mg titreated up to 100 mg or down to 25 mg based on investigator's judgment of efficacy/ tolerability Duration: 8 wks Frequency: up to once/d Compliance: NR CG: Dose: NA Duration: 8 wks Frequency: as IG Compliance: NR Run In period: NR Wash out period: 2 wks F/u duration: end of each 8 wks study period Other: mean number of tablets= sildenafil 24.3 (3.3); placebo 23.8 (2.6) | Primary outcome results: IIEF, mean (sd): Q3: baseline 2.28 (0.72); post tx 3.9 (0.85) vs. 2.28 (0.73), P<0.001 Q4: baseline 2.09 (0.92); post 3.80 (0.66) vs. 2.15 (0.98), P<0.001 EF: baseline: 13 (3.3); post tx 22.3 (3.3) vs. 13.3 (3.43), P<0.001 OF: baseline 5.4 (1.8); post 10.4 (2.0) vs. 5.4 (1.77), P<0.001 SD: baseline 6.3 (1.4); post 6.65 (1.0) vs. 5.9 (1.99), P<0.32 IcS:baseline 5.1 (5.4); post 7.7 (1.4) vs. 5.4 (1.99), P<0.001 OS: baseline 4.8 (0.97); post 7.31 (0.9) vs. 5.1 (1.31), P<0.001 GEQ-1, % improved: 81.3% vs. 18.7% Other outcomes assessed: individual IIEF questions (Q13 placebo effect) Withdrawals/drop-outs/loss to f/u, n (%): 1 (<1) WDAE, n (%): 1 (<1) TAE, n (%): NR (AE included headache, flushing, generalized body ache, and typical bluish visual hallucination in IG) SAE: NR Ascertainment of outcomes assessed: IIEF; diary card; laboratory blood analysis
Sharma (2006) ^75^ Funding source: NR | N screened = NR N randomized = 32 (cross over) IG/ CG, n = 32 ITT analysis used for primary outcome: NR Inclusion: renal transplant men with confirmed ED, and stable allograft function for the preceding 6 mo; in a stable relationship Exclusion: proliferative diabetic retinopathy or penile anatomic deformity; recent stroke | Age, mean: 40 y Race: NR Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED, mean: 17 mo Underlying disease, n (%): renal surgery Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG: Sildenafil CG: Placebo IG: Dose: 50 mg Duration: 8 wks Frequency: 1 hr before sexual activity Compliance: NR CG: Dose: NA Duration: 8 wks Frequency: as IG Compliance: NR Run In period: NA Wash out period: 2 wks F/u duration: 18 wks; evaluation at end of each 8 wks tx period | Primary outcome results: IIEF, scores: NR IG: improved in all questions (except SD domain), p<0.001 CG: ▴ only for Q13 (relationship satisfaction), p=0.03 GAQ, % improved: 81.3% vs. 18.7%, p</=0.01 Other outcomes assessed: concentration of ciclosporin assessed in n=5; serum creatinine level; blood urea nitrogen Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): NR TAE, n (%): 8 (25) vs. 2 (6.3) Headache 5 (15.6) vs. 2 (6.3); rhinorrhea and flushing 2 (6.3) vs. 0; blush visual hallucination 1(3.1) vs. 0 SAE, n (%): NR Ascertainment of outcomes assessed: IIEF; GAQ
Sommer (2007) ^76^ Funding source: No outside support | N screened = NR N randomized = 112 (open label; also reported on n=18 non randomized who refused treatment) IG, n = 56 CG, n = 56 ITT analysis used for primary outcome: yes Inclusion: men 20–70 y with ED defined by IIEF -EF score of <26 for at least 6 mo in duration with mild to moderate, arteriogenic aetiology and responsive to ED treatments (PDE-5 or IC injection) Exclusion: penile anatomical abnormalities, primary hypoactive SD, ED of endocrine origin, radical pelvic surgery without erection, poorly controlled DM, or clinically sign. liver kidney, CV, or CNS disorders. Non responders to ED treatment (8 trials of sildenafil 100 mg, or 40 μg IC injection of PgE1), also pts with concurrent tx with nitrates, androgens or anticoagulants | Age, mean (range): 44.7 vs. 46.1 y Race: NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: BMI, mean (kg/m^2^)= 26.9 vs. 27.7 ED severity at baseline, IIEF-EF: Severe=0 Moderate (11–16), 16 (29) vs. 20 (36) Mild to moderate (17–21) 28 (50) vs. 28 (50) Mild (22–25) 12 (21) vs. 8 (14) Peak flow velocity, men (sd): 25.8 (7.5) vs. 23.1 (6.9) cm/s | Concomitant medications: NR Duration of ED, mean: 4.3 vs. 5.5 y Underlying disease (% of pts): NR Psychogenic ED (%): NR Physiologic ED (%): NR Mixed ED (%): NR | IG1: sildenafil IG2: sildenafil IG1-3: Dose: 50 mg Duration: 12 mo Frequency: every evening at bedtime Compliance: NR IG: Dose: 50 or 100 mg on demand for anticipated sexual activity Duration: 12 mo Frequency: Compliance: NR Run In period: 4 wk Wash out period: NR F/u duration: 18 mo | Primary outcome results: % of pts with normal (at least 26) IIEF-EF at 12 mo: 32/48 (66.7%) [95% CI 51.6–79.6] vs. 33/49 (67.3%) [95% CI 52.5–80%] 28/48 (58.3%) [95% CI 43.2–72.4%] vs. 4/49 (8.2%) [95% CI 2.3–19.6%] had normal EF domain scores 6 mo after completing the course of study Other outcomes assessed: PSV of cavernous arteries improved by 11.2 cm/s (95% CI 4.7–21.4; p=0.012) from 25.8 (7.5) to 37 (10.4) after 4 wks washout period (IG1); improved by 3.4 cm/s (95% CI -5.1–14.7; p=0.435) Withdrawals/drop-outs/loss to f/u, n (%): 8 (14.3) vs. 7 (12.5) WDAE, n (%): 4 (7) vs. 4 (7) TAE, n (%): NR (AE included rhinitis in one man (IG1) vs. headache in 5, flushing in four, dyspepsia in four, and rhinitis in two (IG2) SAE: 0 Ascertainment of outcomes assessed: IIEF
Stuckey (2003) ^77^ Funding source: Pfizer Inc, New York | N screened = 244 N randomized = 191 IG, n = 97 CG, n = 94 ITT analysis used for primary outcome: NR Inclusion: men 18 or older with clinical dx of ED for at least 6 mo and controlled type 1 diabetes for longer than 1 y (HbA1c levels < 11%); in a stable heterosexual relationship Exclusion: penile anatomical deformities, major psychiatric disorder, hx of alcoholism, substance abuse, SCI, MI, stroke, heart failure, unstable angina, nitrate use; severe autonomic neuropathy, diabetes secondary to pancreatic damage; cushings syndrome or acromegaly | Age, mean (range): 47(25–69) y Race (%): White: 96 vs. 91; Black: 0 vs. 2; Asian: 4 vs. 7 Co-morbidities: unspecified GI 6 (9) vs. 5 (8); unspecified disorders of eye: 21 (32) vs. 14 (21) HbA1C, % (range): 9 (6–13) Previous ED treatment, %: 28.4 vs. 20.4 including IC, and IU injections; pump; and sildenafil (reported dose only in IG, =28% used 50 mg, and 72% used 100 mg) Smoking status: Current 40 vs. 29 Body weight, mean (range): 80 (56–118) vs. 77 (53–139) kg | Concomitant medications, %: Insulin: 100 (all pts) Oral antidiabetic: 3.2 vs. 2.1 Duration of ED, mean (range): 5 (0.6–19) vs. 6 (0.7–27) Underlying disease, %: CVD=34 vs. 39; hypertension= 30 vs. 33; Peripheral vascular dx: 1 vs. 5; DM 10 (15) vs. 8 (12) Psychogenic ED, %: 0 vs. 1 Physiologic ED, %: 79 vs. 66 Mixed ED, %: 21 vs. 33 | IG: sildenafil citrate CG: placebo solution IG: Dose: 50 mg, option to titrate to 100 mg or 25 mg Duration: 12 wks Frequency: once/d Compliance (%): 88 CG: Dose: NA (titration as IG) Duration: 12 wks Frequency: once/d Compliance (%): 82 Run In period: 4 wks Wash out period: NR F/u duration: 12 wks | Primary outcome results: IIEF Q3, improvement in mean scores from baseline, %: 36 vs. 20; post tx, mean (sd): 4 (0.5) vs. 3 (0.5) IIEF, Q4, improvement in mean score from baseline, %: 68 vs. 27; post tx, mean (sd): post tx: 3 (0.5) vs. 2 (0.5) GAQ, % yes: 66 vs. 29 Successful intercourse, %: 63 vs. 33 Other outcomes assessed: subgroup analysis based on severity of ED for IIEF- OF; SD, intercourse satisfaction and OS (all values in figures); all sign better in IG vs. CG Withdrawals/drop-outs/loss to f/u: 8 (8) vs. 7 (7); including lack of efficacy: 2 (2) vs. 3 (3) WDAE, n (%): 1 (1) vs. 2 (2) TAE: 48.4vs. 14 (n of AEs); including headache 20% vs. 7.5%; flushing 18% vs. 3%; dyspepsia 8% vs. 1%; visual disturbances 2% vs. 2% (headache, flushing and dyspepsia in >5% of pts) SAE, n (%): 0 vs. 1 (1) Ascertainment of outcomes assessed: IIEF, GAQ; Questionnaires, personal diary logs
Tan (2000) ^78^ Tan (2002) ^79^ Funding source: Pfizer pharmaceuticals group (South East Asia Region) | N screened = NR N randomized = 254 IG, n = 127 (final n=119) CG, n = 127 (final n=119) ITT analysis used for primary outcome: yes (n=16, 8 in each grp were excluded from analysis) Inclusion: men 26–78 with ED of at least 6 mo, in a stable heterosexual relationship for at least 6 mo Exclusion: genital anatomic abnormalities, SCI, co-existing sexual disorders, PRL levels 3 times higher than ULT, free T 20% below lower limit of normal in morning; hx of major psychiatric disorders, alcoholism, substance abuse, major hematologic, renal or hepatic abnormalities, stroke, MI, sign CVD for under 6 mo; hypotension, poorly controlled DM, retinopathy, retinitis pigmentosa, androgens, trazodone, nitrates or nitric oxide donor agents | Age, mean (range): 52 (31–78) vs. 51 (26–70) Race (%): 100 Asian Co-morbidities: NR Previous ED treatment: NR Smoking status, n (%): 36 (28) vs. 34 (27) Initial body weight, mean: 72 vs. 71 kg | Concomitant medications: Antidiabetic drugs 87 (34); antihypertensives 67 (26); lipid-lowering drugs 23 (9) Duration of ED, mean: 3.6 y Underlying disease, n (%): DM 91 (36); hypertension 61 (24); visual disturbance: 47 (19) Psychogenic ED, n (%): 15 (12) vs. 18 (14) Physiologic ED, n (%): 82 (65) vs. 78 (61) Mixed ED, n (%): 30 (24) vs. 31 (24) | IG: oral sildenafil CG: oral placebo IG1: Dose: 50 mg with option to titrate to 100 or 25 mg Duration: 12 wks Frequency: up to once/d Compliance (%): NR CG: Dose: NA Duration: 12 wks Frequency: up to once/d Compliance (%): NR Run In period: 4 wks Wash out period: NR F/u duration: NR | Primary outcome results: IIEF mean scores IG vs. CG: IIEF-Q3: 4.2 vs. 2.6 IIEF-Q4: 4.2 vs. 2.4 IIEF-EF: pre=13.3; post: 25 vs. 15.5 IIEF-OF: pre=5.6; post: 8.6 vs. 3.4 IIEF-SD: pre=7; post: 8 vs. 7 IIEF-IS: pre=6.7; post: 10.7 vs. 8.4 IIEF-OS: pre =4.5; post: 8.4 vs. 5.1 GAQ, % yes: 87 vs. 33 Intercourse success, %: 78 vs. 29.6 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 11 (4) WDAE, n (%): 1 (<1) vs. 1 (<1) TAE, n (%): 42 (33) vs. 29 (23), AE reported in at least 2 pts=body as a whole 18 (14) vs. 21 (17); CV events 13 (10) vs. 6 (5); respiratory system = nervous system events 7 (6) vs. 5 (4); digestive system events 5 (4) vs. 1 (0.8); special senses 5 (4) vs. 0; musculoskeletal events 4 (3) vs. 3 (2); laboratory abnormalities 2 vs. 3 SAE, n (%): 1 (<1) vs. 1 (<1); one severe angina pectoris 4 hr post medication with 100 mg sildenafil; one accidental hand injury in CG Ascertainment of outcomes assessed: IIEF, sexual activity & medication logs, GEQ, physical exam
Tignol (2004) ^80^ Funding source: Pfizer Inc. (authors also supported by Pfizer) | N screened = 170 N randomized = 168 IG, n = 83 CG, n = 85 ITT analysis used for primary outcome: Yes Inclusion: men 18 or older, with ED, and in a stable relationship with a female partner for at least 6 mo Exclusion: major psychiatric disorder other than depression, ongoing major depressive disorder, reactive depression, hypotension, hypertension, stroke, MI, CVD, taking nitrates within 2 wks of entry | Age, mean (sd): 53 (10) y Race (%): White (100%) Co-morbidities, %: hypertension 10.8 vs. 16.5; DM 8.4 vs. 7.1 Previous ED treatment: median duration: 89 (4–133) d vs. 86 (13–154) d Smoking status, %: present smoker 31.3 vs. 34.1 Body weight: NR Other: mean (range) depression duration 4.8 (0–28.5) vs. 3.1 (0.2–20.5) y | Concomitant medications, %: antihypertensives = 13 vs. 14; diabetes drugs= 10 vs. 6 Duration of ED: 4.3 (0.4–20.8) vs. 4.2 (0.3–32.9) y Underlying disease: NR Psychogenic ED, n (%): 51 (61) vs. 64 (75) Physiologic ED, n (%): 5 (6) vs. 2 (2.) Mixed ED, n (%): 27 (33) vs. 19 (22) | IG: sildenafil CG: placebo IG: sildenafil Dose: 50 mg (flexible dosing) Duration: 12 wks Frequency: once/d Compliance (%): NR CG: placebo Dose: NR Duration: 12 wks Frequency: once/d Compliance (%): NR Run In period: 4 wks Wash out period: NR F/u duration: 12 wks | Primary outcome results: IIEF Q3: IG: NR vs. CG: NR, p < 0.0001 (improved in IG) IIEF Q3: IG: NR vs. CG: NR, p < 0.0001 (improved in IG) Successful intercourse attempts, % = 74 vs. 29, p = 0.0001 GAQ, % yes: 83 vs. 34 Other outcomes assessed: mean IIEF scores for 5 other functional domains demonstrated in figures, mean Life Satisfaction Checklist (LSC) score Withdrawals/drop-outs/loss to f/u: 9 (11) vs. 10 (12) WDAE, n (%): 1 (1) vs. 0; also 3 (4) vs. 2 (2) temporarily discontinued or reduced dose TAE, n (%): 34 (41) vs. 14 (17); most common AEs were headache and flushing; abnormal vision in 2 (2) vs. 1 (1) including a change in colour vision (bluish tinge) in placebo SAE: NR Ascertainment of outcomes assessed: Questionnaires (IIEF, LSC, GEA)
Ugarte (2002) ^81^ Funding source: Pfizer Inc. | N screened = 249 N randomized = 242 IG1, n = 123 IG2, n = 119 CG, n = NA ITT analysis used for primary outcome: Y Inclusion: men 18 or older, with mild to moderate ED for at least 6 mo; in stable sexual relationship with female partner Exclusion: psychological or social risk factor for entering the trial; genital /anatomic deformity impairing erection; ED due to another primary sexual disorder, SCI or radical prostatectomy, marked liver function abnormality, hx of gastroduodenal ulceration, retinitis pigmentosa); use of investigational drugs in last 6 wk; or medications associated with ED unless prescribed 2 wk before study entry and no dosage adjustments anticipated; use of nitrates, nitric oxide donors or alpha blockers | Age, mean (range): 53.6 (25–75) vs. 55.2 (28–80) y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight, mean (range): 79.9 (43–115) vs. 77.1 (51–155) kg | Concomitant medications: NR Duration of ED (range): 6 mo - 34 y Underlying disease: NR Psychogenic ED, n (%): 19 (15.4) vs. 17 (14) Physiologic ED, n (%): 42 (34) vs. 41 (34.5) Mixed ED, n (%): 62 (50) vs. 61 (51) | IG1: sildenafil citrate IG2: phentolamine IG1: Dose: 50 mg, titration option to 25 or 100 mg Duration: 8 wk Frequency: up to 1 dose/ d; 1 hr before sexual activity; max. 1/day Compliance (%): NR IG2: Dose: 40 mg Duration: 8 wk Frequency: up to 1 dose/ d; 30 minutes before sexual activity Compliance (%): NR Run In period: 4 wk Wash out period: NA F/u duration: 13 wk | Primary outcome results: IIEF domain scores, Least square mean score (sd): EF: pre= 16.3 vs. 15.4; post: (1–5,15): 27.2 (0.6) vs. 19.4 (0.7) OF (9,10): pre= 6.6 vs. 6; post: 9.3 (0.2) vs. 7.5 (0.2) SD (11,12): pre=6.8; post: 7.9 (0.1) vs. 7 (0.1) IC s (6–8): pre=8.2 vs. 7.9; post: 13.7 (0.3) vs. 1.3(0.3) OS (13,14): pre= 4.8 vs. 4.6; post: 8.5 (0.2) vs. 5.7 (0.2) GEQ, improved erection % yes: 95 vs. 51 GEQ, improved sexual ability % yes: 94.4 vs.46.4 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 29 (12) WDAE, n (%): 1 (<1) vs. 4 (3.4) TAE, n (%): 41 (33) vs. 49 (41), pts with at least 3% incidence of AE including headache 14 (11.4) vs. 6 (5); rhinitis 6 (5) vs. 15 (12.6); flushing 5 (4) vs. 3 (<1); tachycardia 1 (0.8) vs. 7 (5.9); nausea 1 (0.8) vs. 6 (5) SAE: 1 (0.8) vs.3 (2.5) Ascertainment of outcomes assessed: IIEF; EF and other domains; GEQ (two questions); event log of sexual function
Webster (2004) ^82^ Funding source: Grant from University of Alberta Hospital Foundation | N screened = 41 N randomized = 35 (cross over) IG/ CG, n = 35 ITT analysis used for primary outcome: Yes Inclusion: pts with moderate to severe heart failure who had documented ED Exclusion: Pts with hypotension or SBP less than 80 mmHg; hx of myocardial ischemia, receiving psychotropic tx, hx of drug/alcohol abuse, abnormal ECG | Age, mean (SEM): 60 (2) y Race (%): NR Co-morbidities, %: ischemia 60; idiopathic 26; hypertension 69; DM 26 Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, %: ACE inhibitors=β-blockers 94; diuretics 89; aspirin 66, coumadin= digoxin 63; Ca channel blocker 11 Duration of ED: NR Underlying disease: CHF Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: Mean (SEM) IIEF score = 9(1) | IG: Sildenafil CG: Placebo IG1: Sildenafil Dose: 50 mg Duration: 6 wks Frequency: once/d Compliance: 100% CG: Placebo Dose: NR Duration: 6 wks Frequency: as IG Compliance: 100% Run In period: NR Wash out period: NR F/u duration: before and after crossover 12 wks | Primary outcome results: Mean (SE) IIEF score (IG1 vs. CG) before crossover at 6 wks = improved in IG1 (p < 0.001) Mean (SE) IIEF score (IG1 vs. CG) after crossover = improved in IG1 (p < 0.001) Overall response on IIEF scores before and after crossover (IG1-CG vs. CG-IG1) = NS (p=0.98) Other outcomes assessed: Mean scores of IIEF (shown in figure); no sign reduction of BP, or HR in IG Withdrawals/drop-outs/loss to f/u: 0 WDAE: NR TAE: NR; arterial fibrillation in 2 (5.7); heart failure/dyspnea 1 (2.8), all during placebo phase SAE: 2 deaths (study personnel) Ascertainment of outcomes assessed: IIEF Questionnaire
Young (2002) ^83^ Funding source: Pfizer Inc. | N screened = blacks (B) 310, Hispanics (H) 257 N randomized = 443 (B, n =246, H, n = 197); open label, n = 191 (B=211; H=144) IG, n =223 (B= 124, H = 99) CG, n =220 (B= 122, H =98) ITT analysis used for primary outcome: Yes Inclusion: black American or Hispanic American, 18 or older; documented clinical diagnosis of ED for longer than 6 mo; in stable relationship Exclusion: previous txt with sildenafil for ED; other sexual disorders as primary dx; ▴ PRL levels or low free-T levels; uncontrolled DM; hx of stroke or MI within previous 6 mo; ED as consequence of SCI; concomitant use of nitrates, androgens or trazodone | Age, mean (sd): B= 53 (25–73) vs. 54 (23–81) H=55 (31–84) vs. 53 (22–75) y Race, n (%): black 246 (56), Hispanic 195 (44) Co-morbidities: % with ≥1 current medical condition B= 90; H= 90 vs. 86 Previous ED treatment: NR Smoking status (%): current B= 38 vs. 31; H= 18 vs. 26 Body weight, mean (range): B=95 (50–182) kg H= 85 (56–133) kg | Concomitant medications: % with any B= 86 vs. 87 H =80 vs. 75 Duration of ED, mean (range): B= 4 (0.3–33) vs. 5.2 (0.3–30) H= 4 (0.2–43) vs.3 (0.2–20) y Underlying disease: NR Psychogenic ED (%): B=13; H 10 vs. 11 Physiologic ED (%): B =56 vs. 54; H= 66 vs. 60 Mixed ED (%): B 32 vs. 33; H 24 vs. 29 Other: Severity of ED (%) Mild to moderate: B= 61 vs. 60, H= 46 vs. 62; Severe, B =31 vs. 30, H =39 vs. 26 | IG: sildenafil CG: placebo IG: Dose: 50 mg, option to titrate to 100 or 25 mg Duration: 12 wk Frequency: up to. 1/d, one hr before sexual intercourse Compliance (%): NR CG: Dose: placebo Duration: 12 wk Frequency: as IG Compliance (%): NR Run In period: None Wash out period: None F/u duration: 12 wk parallel (option to switch to opposite arm during the 12 wk parallel period)+ 12 wk of open-label tx extension (safety results shown) Other: results reported for 6 wks post intervention; n of pts who switched also reported | Primary outcome results: IG vs. CG, (B-H where not equal), mean score at 6 wks: IIEF, Q3: pre: 2.6–2.4; post: 4 vs. 3 IIEF, Q4: pre: 2; post 4 vs. 3 IIEF, EF: pre 14; post 23 vs. 18–16 IIEF, OF: pre 6; post: 8 vs. 6–7 IIEF, SD: pre 7; post 7 vs. 7–6 IIEF, ICs: pre: 6–7; post 11 vs. 9–8 IIEF, OS: pre 4–5; post 8 vs. 6 GEQ-Q1, %: B: 79 vs. 38; H: 82 vs. 30 GEQ-Q2, %: B: 81 vs. 36; H: 80 vs. 29 GEQ-Q3: B: 4 vs. 3; H: 3.5 vs. 2.5 Other outcomes assessed: barriers to tx; subgrp ED severity; EDITS, EPQ Withdrawals/drop-outs/loss to f/u: B: 6 (5) vs. 10 (10); H: 13 (11) vs. 9 (9) Open label phase, B: 20 (9), H: 19 (13) WDAE, n (%): B=0; H: 2 (2) vs. 0 TAE, n (%): 12 wks, B: 18 (15) vs. 3 (3); H: 27 (22) vs. 11 (11); most common, % in IG/ pts switched to IG vs. CG: headache B: 11 vs. 2; H: 16/12 vs. 7; vasodilation B: 2 vs. 0; H: 7/9 vs. 2; rhinitis B: 2 vs. 0; H: 2/4 vs. 0; nausea B: 1 vs. 0, H: 2/1 vs. 0; dizziness B: 0; H: 3/1 vs. 0; abnormal vision B: 2 vs. 0, H: 2/1 vs. 0 SAE, n (%): 1 (<1) in IG (H) Ascertainment of outcomes assessed: IIEF, GAQ; EDITS; erection problem question (EPQ)
Zinner (2007) ^84^ Funding source: Pfizer Inc. (conflict of interest: author has spoken for Pfizer) | N screened = N randomized = 48 (double cross over design- impact of food) IG/CG 1&2, n = 24 IG/CG 3&4, n = 24 ITT analysis used for primary outcome: NR Inclusion: men 18 or older in a stable relationship or 6 mo or longer taking 50 or100 mg sildenafil; with IIEF of 25 or less and minimum 4 sexual attempts/ mo Exclusion: no response to sildenafil 100 mg; CVD in last 3 mo; current use or likely prescription of nitric oxide donors; use of an alpha-blocker; use of other ED tx; hx of retinitis pigmentosa; tx with ritonavir, or an investigational drug within 6 wks of screening; any known medical or psychological conditions; blood donation within 4 wks; drug or alcohol abuse; potential non-compliance | Age, mean (range): 57 (29–79) y Race: NR Co-morbidities, n (%): heart disease IG1&2= 4 (16.7) IG3&4 =1 (4.2) Previous ED treatment: 100% had been treated with sildenafil 50 or 100 mg Smoking status: NR Body weight: NR Other: recreational drug use, n (%) IG1-2= 14 (58.3) IG3–4= 19 (79.2) | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): NR Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG1-4: Sildenafil CG1–4: placebo IG1-4 (sildenafil): Dose: 100 mg Duration: 16 wks (4 wk s/ tx period) Frequency: 1 hr berore meal (IG1); 30–60 min before sexual activity (IG2&4); during meal (IG3) Compliance: CG1–4 (placebo): Dose: NA Duration: 16 wks as IG Frequency: 30–60 min berore coitus (IG1&3); 1 hr before meal (IG2); during meal (IG4) Compliance: Run In period: 1–2 wks (stopped sildenafil dosing) Wash out period: NR F/u duration: end of each tx period | Primary outcome results: IG1 vs. IG2 & IG3 vs. IG4 IIEF-EF change from baseline, mean: 11.4 vs. 11.4 & 11.2 vs. 11.2 SEP-Q2 intercourse attempts: 93.9% vs. 91.8% & 91.4% vs. 92.6% SEP-Q3: 84.7% vs. 85.9% & 83.4% vs. 87.5% Time between dosing and intercourse attempt ▾ responses to SEP-3 (from max 92.8% at 1.5–2 hr to 81.6% when taken >10 hrs prior to coitus) Other outcomes assessed: mean interval between dosing and coitus in IG2 & IG4 =1.3 (0.6) & 1.1 (0.5) hr Intervals between dosing and coitus in IG1 & IG4= 4.8 (1.8) & 3.6 (1.9) hr No sign differences for EDITS responses or preference and satisfaction for any of the regiments Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): NR TAE: NR SAE, n (%): NR Ascertainment of outcomes assessed: IIEF; SEP- Q2 & 3; EDITS

List of abbreviations: %=percent, ▴=increased, ▾=decreased, AE=adverse event, SAE=serious adverse event, BMI=body mass index, CC=controlled clinical trials, CG=comparator/control group, ctrls=controls, DM=diabetes mellitus, E_1_ IC=intracavernosal injection, ECG=electrocardiograms, ED=erectile dysfunction, EDV=end-diastolic velocity, f/u=follow-up, FMD=flow mediated dilation, GAQ=global assessment question, GEQ=global efficacy question, grp=group/s, HbA1C=haemoglobin, hr=hour(s), hx=history, IG=intervention group, IIEF= international index of erectile function (EF=erectile function, OF=orgasmic function, OS=overall satisfaction, SD=sexual desire), ITT=intent-to-treat (Y = yes, N = no, NR = not reported), IU=intraurethral, kg=kilograms, lbs=pounds, LUTS=lower urinary tract symptoms, M=male, max=maximum, mo=month(s), NA=not applicable, PADAM=partial androgen deficiency of the aging male, PgE_1_=Prostagladin, PRL=prolactin, PSA=prostate-specific antigen, RAU=rigidity activity unit, RCT=randomized control trial, SBP=systolic blood pressure, sign.=significant; TAE=total adverse events, TAU=tumescence activity unit, vs.=versus, WDAE=withdrawals resulting from adverse events, wk=week(s), yr=year(s).

Evidence Table C2. Oral Vardenafil

Author Funding | N; study design; eligibility | Participants characteristics | Diagnosis details | Intervention | Outcomes
Carson (2004) ^85^ ^86^ Companion Hatzichristou (2005) ^86^ Funding source: Bayer Corporation and GlaxoSmithKline | N screened = NR N randomized = 463 IG, n = 233 CG, n = 230 ITT analysis used for primary outcome: yes(N = 454, n = 229 vs. n = 225) Inclusion: men 18 or older with ED, no response to 100 mg sildenafil indicated by at least 4/ 6 unsuccessful intercourse attempts; in heterosexual relationship for past 6 mo Exclusion: penile anatomical abnormalities; hypoactive SD; ED due to SCI or radical prostatectomy; retinitis pigmentosa; hepatitis B, C surface antigen or; unstable angina pectoris; MI, stroke, ischemia; DM; hypotension; use of anticoagulants, androgens, trazodone, antiandrogens, alpha1 antagonist, potent HIV protease inhibitor, nitrates, itraconazole, ketokonazole, erythromycin (more in full text) | Age, mean (range): 60 (29–83) vs. 59 (23–88) y Race, n (%): White: 404 (87); Asian: 18 (10); Hispanic: 14 (3); Black: 13 (3); Other: 5 (1) Co-morbidities: NR Previous ED treatment: Sildenafil up to 100 mg BMI, mean (sd): 29 (4) vs. 28 (4) kg/m^2^ Body weigh: NR Other: Severity of ED, Severe: 242 (52); moderate 164 (36); mild to moderate 9 (2); mild 8 (2) IIEF-EF domain= 9.3 vs. 9.7 | Concomitant medications: NR Duration of ED, mean (sd): 5 (4) y Underlying disease, n (%): Hypertension 90 (39) vs. 92 (41) DM 78 (34) vs. 7 (25); Benign prostatic hyperplasia: 39 (17) vs. 40 (18); CAD 8 (3) vs. 11 (5) Psychogenic ED, n (%): 8 (3) vs. 20 (9) Physiologic ED, n (%): 148 (65) vs. 128 (57) Mixed ED, n (%): 3 (32% vs. 77 (34) | IG: vardenafil CG: Placebo IG: Dose: 10 mg (option to titrated to 5 or 20 mg at 4 and 8 wks) Duration: 12 wks Frequency: max 1/d Compliance: 99% [n=2 (<1%) did not complete] CG: Dose: NA Duration: 12 wks Frequency: as IG Compliance: 98%; [n=4 (2%) did not complete] Run In period: NR Wash out period: 24 hrs F/u duration: 12 wks + 24 hrs post final visit. Note: topical formulas were allowed in this study; investigational drugs within 30 days of screening therapy for ED within 7 d or vardenafil at any time prior to study. | Primary outcome results: IIEF-EF: baseline=<10 (severe ED); post tx pts with normal scores, n (%)=67 (31) vs. 12 (6) SEP-Q2, % yes, n (%): 0.25 hr post dosing= 57 (62) vs. 55 (30) >6 hr post dosing= 30 (77) vs. 18 (50) SEP-Q3, % yes, n (%): 0.25 hr post dosing= 57 (53) vs. 55 (12) >6 hr post dosing=30 (70) vs. 17 (24) GAQ, % yes: 61.6% vs. 15% 61.8% vs. 14.7% at LOCF, p<0.001) Other outcomes assessed: intercourse attempts data Withdrawals/drop-outs/loss to f/u, n (%): 25 (11) vs. 41 (18); including insufficient tx effect in 5 (2) vs. 17 (7) WDAE, n (%): 5 (2) vs. 3 (2) TAE, n (%): 40.7% vs. 22.6%; drug related in 2% or more=flushing 16 (7) vs. 2 (1); headache: 15 (6) vs. 4 (2); nasal congestion: 11 (5) vs. 1 (<1); dyspepsia: 8 (3) vs. 0; total mild AE= 55 (24) vs. 20 (9); total moderate AE= 34 (15) vs. 25 (11) SAE, n (%): 7 (3.0) vs. 3 (0.9) Outcome ascertainment: IIEF-EF; SEP, Q2 and 3; GAQ
Demir (2006) ^87^ Funding source: NR | N screened = NR N randomized = 60 IG, n = 39 CG, n = 21 (n=15 with no ED also served as ctrls, data not shown) ITT analysis used for primary outcome: NR Inclusion: men with ED (diagnose with color Doppler Ultrasound and IC injection of 60 mg papaverine) and functioning renal graft (serum creatinine level <2 mg/dL); in a stable relationship with a partner Exclusion: stroke, DM, MI, CHD, overt heart failure; sing penile anatomical deformities active peptic ulcer, chronic liver disease; sign hypo/hypertension; blood coagulation disorders; nitrate tx | Age, mean (sd): 48 (7.4) vs. 50 (7.1) y Race: NR Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): immunosuppressant tx: cycloporine (14+8) or JD506 (25+13); low dose prednisolone and ycophenolate mofetil Duration of ED: NR Underlying disease, n (%): Renal transplant Psychogenic ED, n (%): NR Physiologic ED, n (%): 100% Mixed ED, n (%): NR | IG: Vardenafil CG: Placebo IG: Dose: 10 mg titrated to 20 mg based on efficacy measures Duration: 4 wks Frequency: up to once/d; 1 hr prior to sexual activity Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: NR Wash out period: NR F/u duration: 4 wks | Primary outcome results: IIEF-EF, mean (sd): Baseline 12.8 (3.5) vs. 12.5 (3.7) Post tx 26.46 (2.4) vs. 13.27 (2.8) Tx effect, P<0.001 ED Severity, baseline- post tx in IG: Severe: 3 -0 Moderate 17- 0 Mild to moderate: 9 – 2 Mild 10–4 None 0 – 32 Other outcomes assessed: IIEF individual scores of Q1–5 and 15; serum T, FSH, and LH levels, not sign. between grps (data not provided) Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE: NR TAE, n (%): 7 (18), including headache in 3, palpitation in one, flushing in two and dyspepsia in one SAE: NR Outcome ascertainment: self administered IIEF on renal transplant pts
Edwards (2006) ^88^ Funding source: NR | N screened = 288 N randomized = 260 IG, n = 194 CG, n = 66 ITT analysis used for primary outcome: yes (LOCF; n=254) Inclusion: men 18 or older with ED for at least 6 mo; no prior hx of PDE5i use Exclusion: unstable medical, psychiatric condition; substance abuse; hypoactive SD; SCI, surgical prostatectomy; hereditary degenerative retinal dx; hepatitis B surface angina, hepatitis C, HIV; liver disease; sign hematologic disease; active peptic ulceration; any cardiovascular condition; MI, stroke, serious arrhythmia within 6 mo of entry; uncontrolled hypo/hypertension; hx of malignancy within 5 y; use of nitrates or nitric oxide donors; androgens or any other investigational drug | Age, mean: 53.6 vs. 54.2 Race: NR Co-morbidities, %: DM 27; hypertension 35; Hyperlipidemia 10 vs. 6 Previous ED treatment: Smoking status: NR Body weight: NR Other: BMI, mean 27.4 kg/m^2^ | Concomitant medications, n (%): NR Duration of ED: 2 y Underlying disease, n (%): NR Psychogenic ED, %: 16 vs. 23 Physiologic ED, %: 29 vs. 24 Mixed ED, %: 55 vs. 53 Other: Baseline IIEF score: 13.6 Severity of ED, %: Severe 29% vs. 39% | IG: Vardenafil CG: Placebo IG: Dose: flexible dose starting dose of 10 mg for 4 wks; adjusted to 5 or 20 mg for the next 8 wks Duration: 12 wks Frequency: NR Compliance: 99% CG: Dose: NA Duration: 12 wks Frequency: NR Compliance: 100% Run In period: 4 wks Wash out period: NA F/u duration: 12 wks (excluding the 4 wks run-in period) | Primary outcome results: IIEF-EF, mean: baseline moderate; post tx 23.5 vs. 15.8; increase on score of 8.8 in IG vs. CG (95% CI 6.4, 11.1; p<0.0001) SEP-2, %: baseline 48 vs. 46 12 wks: 85 vs. 65 SEP-3, %: Baseline: 21 vs. 22 12 wks: 78 vs. 49 GAQ, % improved: 83% vs. 38%, p<0.0001 Other outcomes assessed: TSS, sign better score in IG vs. CG, p<0.0001 Withdrawals/drop-outs/loss to f/u, n (%): 12 (6.7) vs. 4 (6.1) WDAE, n (%): 3 (1.5) vs. 1 (1.5); IG included MI, aortic bifurcation graft; CG muscle cramp TAE, n (%): NR; tx related occurring in 2% or more of pts, %: headache 5.2 vs. 0; flushing 7.3 vs. 0; Influenza 1 vs. 3 SAE, n (%): 2 (1.0) vs. 0; aortic bifurcation graft and MI (MI occurred5 d after last dose of 10 mg); no death occurred Outcome ascertainment: SEP- 2, 3; GAQ; IIEF-EF; Treatment Satisfaction Scale (TSS)
Goldstein (2003) ^89^ Funding source: Bayer Corporation | N screened = 452 N randomized = 452 IG1, n = 153 (ITT = 149) IG2, n = 149 (ITT= 141) CG, n = 150 (ITT= 140) ITT analysis used for primary outcome: Yes Inclusion: men older than 18 y, and clinical diagnosis of type 1 or type 2 DM, Ed of 6 mo or longer. HbA1c ≥12%. Exclusion: ED due to radical prostatectomy, hypoactive SD; SCI. MI, stroke, ischemia; sign arrhythmia; uncontrolled atrial tachyarrhythmia, unstable angina pectoris, liver dx, haematological dx or bleeding disorder, resting hypo/hypertension, retinitis pigmentosa, progressive retinopathy, autonomic neuropathy, migraine headaches; AE or dissatisfaction with Sildenafil; Nitrates, anti androgens, anti coagulant androgens, trazodone hypochloride not allowed | Age, mean (sd): 57 (NR) y Race n (%): White 350 (80); Black 41 (9); Hispanic 15 (8) Other 13 (3) Co-morbidities, n (%): Hypertension 231(53); depressive dx 45 (10) HbA1C levels, n (%): ≤ 6 = 12 (3); > 6 to < 8= 192 (43) ≥ 8.0 = 231 (53) Previous ED treatment n (%): Sildenafil 256 (58) Body weight: NR Other: Severity of ED n (%): Severe (<11)=240 (55); Moderate (11–16) 102 (23); Mild to Moderate (17–21): 68 (15); Mild (22–25): 26 (9); Normal [underlined: (]≥ 26): 3 (<1), only in IG2 & CG | Concomitant Medications, n (%): Beta Blockers 52 (12); Renin-angiotension system acting agents 210 (50); Calcium-channel blockers 45 (10); Serum lipid-reducing agents 146 (33); Diuretics 71 (16); Other antihypertensives 40 (9); Insulin 152 (35); Glucose-lowering drugs 318 (72) Duration of ED: 3.5 y Underlying disease: 88% type 2 diabetes and poor glycemic control Psychogenic ED: 2 (<1) only in IG1: 2 (1) Physiologic (organic) ED, n (%): 358 (81) Mixed ED: 77 (18) | IG1: vardenafil IG2: vardenafil CG: Placebo IG1: Dose: 10 mg Duration: 12 wks Frequency: as needed, no more than 1/day Compliance: NR IG2: Dose: 20 mg Duration: 12 wks Frequency: as needed, no more than 1/d Compliance: NR CG: Dose: NA Duration: 12 wks Frequency: as needed, no more than 1/d Compliance: NR Run In period: 4 wk unmedicated phase Wash out period: NR F/u duration: 12 wk | Primary outcome results: IG1 vs. IG2 vs. CG IIEF-EF, mean final score: 17 vs. 19 vs. 13 (change from baseline: 1.4 vs. 6 vs. 8) SEP-Q2, mean least square success rate (%): 61 vs. 64 vs. 36 (in severe ED= NR vs. 40 vs. 11; in mild ED= NR vs. 75 vs. 47) SEP-Q3, mean least square per pts (%): 49 vs. 54 vs. 23 (type I diabetes= 48 vs. 65 vs. 10; type II= 49 vs. 52 vs. 25) GAQ, proportion of men with improved erection: 54% vs. 72% vs. 13% Other outcomes assessed: Blood chemistries, ECG Withdrawals/drop-outs/loss to f/u: 73 (17) WDAE, n (%): 4 (3) vs. 5 (3) vs. 2 (1); headache, cutaneous flushing, rhinitis TAE, n (%): 7 (5) vs. 9 (6) vs. 6 (4) SAE, n: 3 (2) vs. 4 (3) vs. 4 (3); including chest pain, dyspnea, larynx edema, asthma (n=1); depression, hypesthesia, or moderate amnesia; no death occurred Outcome ascertainment: IIEF, SEP, Q2 and 3; GAQ, diary questions
Goldstein (2005) ^90^ ^91^ Companion study, by Fisher (2005) Funding source: Bayer HealthCare (conflict of interest for authors paid by Bayer Health Care) | N screened = NR N randomized = 229 IG, n = 116 CG, n = 113 ITT analysis used for primary outcome: Yes Inclusion: men with ED of 6 mo or longer, previously treated for ED who had a stable heterosexual relationship for => 6 mo with a female partner without sexual disorder, Female Sexual Function Index (FSFI) > 26.55 Exclusion: pts with unstable medical conditions, sign penile deformities, SCI, hx of prostatectomy, retinitis pigmentosa, unstable angina pectoris, MI, uncontrolled atrial fibrillation, taking nitrates or nitric oxide donors, anticoagulants, androgens, antiandrogens, indinavir, intraconazole, or erythromicyn or any ED drug; female partner's having primary hypoactive sexual disorder measured by Female Sexual Function Index | Age, mean (sd): 58 (28–79) y Race (%): White: 85%, Black: 8%, Other: 7% Co-morbidities: NR Previous ED treatment: prior sildenafil in 81% vs. 91% BMI, mean: 29 kg/m^2^ Smoking status: NR Body weight: NR Other: Mean sexual intercourse activity: 6 during run in | Concomitant medications: NR Duration of ED, mean: 4.7 y Underlying disease: NR Psychogenic ED, %: 44.5% Physiologic ED, %: 5% Mixed ED, %: 50% | IG: vardenafil CG: placebo IG: Dose: starting dose 10 mg with option to titrate to 5 or 20 mg at 4 wks Duration: 12 wks Frequency: NR Compliance: NR CG: Dose: NR Duration: 12 wks Frequency: NR Compliance: NR Run In period: 4 wks Wash out period: NR F/u duration: 12 wks | Primary outcome results: IIEF-EF, mean score: baseline: 13; post tx 23 vs.13.5, p < 0.0001 (IG vs. CG) % Success rate of improved least squares mean on Sexual Encounter Profile: SEP-Q2, % yes: 80 vs. 47, p <0.0001 SEP-Q3, % yes: 68 vs. 28, p < 0.0001 Mean Erection Quality Scale (EQS) score: 37 vs. 16, p < 0.0001 (IG vs. CG) Other outcomes assessed: Women's sexual function Withdrawals/drop-outs/loss to f/u: 1 (<1) vs. 0 WDAE, n (%): 1 (<1) in IG; elevated creatinine TAE, n (%): drug related AEs in at least 2% of pts= 22% vs. 4%; including flushing 13 (11) vs. 0; nasal congestion 9 (8) vs. 0; headache 5 (4) vs. 3 (3); dyspepsia 4 (4) vs. 1 (<1) SAE, n (%): 1 (<1) vs. 0; unstable angina Outcome ascertainment: IIEF EF domain (Q1, 5, and 15); SEP Q2 and 3; Erection Quality Scale (EQS)
Hatzichristou (2004) ^92^ ^93^ Funding source: Bayer Corporation, Bayer AG, GlaxoSmithKline | N screened = NR N randomized = 323 IG1, n = 157 (ITT, n = 154) CG, n = 166 (ITT, n = 155) ITT analysis used for primary outcome: Yes Inclusion: men 18 or older with ED (NIH consensus), stable heterosexual relationship for 6 mo or longer, at least 50% of 4 or more attempts at sexual intercourse on 4 separate d during the 4 wk baseline period unsuccessful; answer ‘no’ to at least 1 diary question (IIEF) Exclusion: penile abnormalities, primary hypoactive SD, ED due to SCI; radical prostatectomy, unstable angina, poorly controlled DM, hypertension; liver or hematologic dx; use of organic nitrates, other nitric oxide donors, or potent CYP3A4; sildenafil use permitted except for unresponsiveness or WDAE in last 7 d prior to screening | Age, mean: 54 vs. 53 y Race (%): NR Co-morbidities, (%): hypertension 34 vs. 24; DM 16 vs. 20; hyperlipidemia 2 vs. 5; Cardiac dx 9 vs. 6; respiratory, thoracic Previous ED treatment, (%): Prior sildenafil use 54 vs. 50 BMI, mean: 27kg/m^2^ Smoking status: Non smoker 61 % past smokers Body weight, mean: 81 vs. 82 kg | Concomitant medications: NR Duration of ED, mean: 2 y Underlying disease: NR Psychogenic ED, %: 21 vs. 22 Physiologic ED, %: 37 vs. 42 Mixed ED, %: 43 vs. 36 | IG: Vardendafil (flexible dose) CG: placebo IG1: Dose: 10 mg titrated up or down if desired) Duration: 12 wks Frequency: as needed, no more than 1 dose/d Compliance: NR CG: Dose: placebo (titration as IG) Duration: 12 wks Frequency: as needed, no more than 1 dose/d Compliance: NR Run In period: 4 wks Wash out period: NR F/u duration: 12 wk Other: Titration data, n (%) At wk 4- down to 5 mg: 6 (4) vs. 0 At wk 4-up to 20 mg: 95 (61) vs. 136 (88) At wk 8- down to 5 or 10 mg: 7 (5) vs. 1 (<1) At wk 8- up to 20 mg: 20 (13) vs. 4 (3) | Primary outcome results: IIEF- EF, mean: Baseline=12.8; post tx: 24 vs. 16 SEP-Q2 (% yes): 84 vs. 53 SEP-Q3 (% yes): 74 vs. 34 GAQ; (% yes): 86 vs. 33 Erection hardness mean (%): 63 vs. 23 OS (%): 65 vs. 28 Penis enlargement (%): 92 vs. 75 Successful ejaculation (%): 79 vs. 56 (all p<0.005) Other outcomes assessed: sub-grp by dose; depression; self confidence Withdrawals/drop-outs/loss to f/u: 22 (14) vs. 45 (29) WDAE, n (%): 5 (3) vs. 3 (2); tx emergent AEs only: abdominal pain, headache, dysphagia, pneumonia vs. accidental injury, vascular anomaly, ▴ CPK) TAE, %: pts with at least one AE = 45 vs. 27 (data provided for AE of 2 or more incidence= flushing, headache, rhinitis, flu syndrome, dyspepsia, back pain, CPK increase, dizziness, accidental injury, hypertension and QT interval prolonged); total n of AE= 94 vs. 50 SAE: 4 (2.5) vs. 5 (3); cause NR Outcome ascertainment: IIEF, GAQ; SEP question 2 and 3; pts diary
Hellstrom (2002) ^94^ ^95^ ^96^ ^97^ Funding source: Bayer Pharmaceutical & Bayer Inc. | N screened = 1311 N randomized = 805 (parallel grps) IG1: n= 193 IG2: n = 199 IG3: n = 188 CG: n = 182 ITT analysis used for primary outcome: Yes (n=749; safety population: n=762) Inclusion: heterosexual men 18 y or older with ED, > 6 mo in duration; also with 50% or more failure rate in maintaining erection on at least 4 intercourse attempts on 4 separate d before tx Exclusion: Ed due to SCI, radical prostatectomy, retinitis pigmentosa, angina pectoris or poorly controlled DM; primary hypoactive SD, no response to sildenafil, hx of hepatitis B or C, & concomitant use of nitrates Note: Data reported as IG1 vs. IG2 vs. IG3 vs. CG | Age, range: 57–78 y (mean range per grp 57–58 y) Race, %: Caucasian 77 vs. 80 vs. 82 vs. 77 Co-morbidities: hypertension, prostatic hyperplasia, diabetes type II, depression, prior MI, hyperlipidemia, obesity, all not sign. between grps Previous ED treatment sildenafil (%): 77 vs. 74 vs. 66 vs. 68 BMI, mean: 29kg/m^2^ Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean: 1^st^ diagnosed: 3.6 vs. 3.6 vs. 4.2 vs. 2.9 y (1^st^ noticed: 5.9 vs. 6 vs. 6.6 vs. 5.1 y) Underlying disease: NR Psychogenic ED, %: 7 vs. 7 vs. 7 vs. 9 Physiologic ED, %: 61 vs. 59 vs. 60 vs. 54 Mixed ED, %: 33 vs. 34 vs. 33 vs. 37 Other: baseline IIEF score: 12.6 vs. 13.4 vs. 12.8 vs. 13.7 | IG1-3: Vardenafil CG: placebo IG1-3: Dose: IG1 = 5 mg; IG2 = 10 mg; IG3= 20 mg Duration: 26 wks Frequency: once/ d Compliance (%): NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance (%): NR Run In period: 4 wks Wash out period: NA F/u duration: 26 wks (1 wk post last tx) | Primary outcomes: IIEF- mean score (LOCF), IG vs. CG: EF, Baseline=14; post tx: 18–22 vs. 15 IS (Intercourse satisfaction): 10 vs. 8 OS: 7 vs. 5 SEP-Q2, % yes: Baseline: 43 vs. 45 vs. 41 vs. 46 Post tx: 66 vs. 76 vs. 81.1 vs. 52 SEP-Q3: Baseline=15; Post tx: 52–67 vs. 33 GAQ, % yes: 65 vs. 80 vs. 85 vs. 28 Other outcomes assessed: self reported erection hardness; satisfaction with intercourse, and OS Drop outs: n=297 (37%): 38% vs. 27% vs. 30% vs. 54% (non compliance, consent withdraw, insufficient tx effect, protocol violation, & lost to F/u) WDAE, n (%): 8 (4.1) vs. 7 (3.5) vs. 15 (7.9) vs. 4 (2.2) reasons reported only for IG=headache, abnormal liver function, nausea, and kidney calculus TAE: NR; AEs included headache, rhinitis, flushing, dyspepsia, accidental injury; all numerically more frequent in IG compare to CG SAE (%): 5 vs. 3 vs. 4 vs. 5 (one MI, no death) Outcome ascertainment: IIEF, GAQ, diaries, SEP, Q2 and 3
Ishii (2006) ^98^ Funding source: Bayer Yakuhin Ltd. | N screened = 954 (enrolled) N randomized = 780 IG1, n = 340 IG2, n = 339 CG, n = 111 ITT analysis used for primary outcome: yes (12 wks LOCF) Inclusion: men with ED (according to NIH Consensus statement) and DM > 3 y; currently under hypoglycemic drug tx or HbA_1c_>6.5% at visit 1; Exclusion: penile deformities; substance abuse; major heart or liver disorders; SCI, MI, hx of hepatitis B, or C, HIV infection; cancer; hypo/hypertension; prostatectomy; retinitis pigmentosa; tx with; non respondent to PDE5i; ED tx within 7 d of trial entry (randomization); low T levels; elevated creatinine levels; tx with nitrates or nitric oxides (other criteria listed in detail in full report) | Age, mean (sd): 53 (7.7); range 26–64 Race: Asian 100% (Japanese) Co-morbidities, n (%): NR Previous ED treatment: sildenafil 296 (37) Smoking status: NR Body weight, mean: 71.8 kg | Concomitant medications, n (%): Medication for DM Duration of ED: 5.4 y Underlying disease, n (%): DM Psychogenic ED, n (%): 0 Physiologic ED, n (%): 720 (92.3) Mixed ED, n (%): 58 (7.7) Other: ED severity on EF domain score, n (%): < 11: 275 (35.4) 11–16: 231 (30) 17–21: 184 (23.8) 22–25: 79 (9.8) | IG1-2: Vardenafil CG: Placebo IG: Dose:20 mg (IG1), 10 mg (IG2) Duration: 12 wks Frequency: 1 hr prior to sexual activity up to 1/d Compliance: NR CG: Dose: NA Duration: 12 wks Frequency: as IG Compliance: NR Run In period: 4 wks no ED tx Wash out period: NA F/u duration: 12 wks | Primary outcome results: IIEF-EF, mean baseline: 13.7 12 wks LOCF, mean: 21.8 vs. 22.9 vs. 16.3 (more evident changes in pts, with baseline EF score of <11) SEP mean % (from graph): SEP- 2: Baseline 37.5 Post tx: 77 vs. 73 vs. 51 SEP-3, Baseline: 12.5 Post tx: 63 vs. 60 vs. 29 Other outcomes assessed: NA Withdrawals/drop-outs/loss to F/u, n (%): 28 (8.4) vs. 11 (3.3) vs. 14 (13.2) WDAE, n (%): 9 (2.7) vs. 2 (0.6) vs. 2 (1.9) TAE, n (%): NR; AE in 2% or more palpitations in 7 (2) vs. 12 (4) vs. 2 (2); nasopharyngitis 17 (5) vs. 31 (9) vs. 6 (6); blood creatinine phosphokinase ▴ 1(<1) vs. 8 (2) vs. 3 (3); headache 20 (6) vs. 13 (4) vs. 2 (2); nasal congestion 6 (2) vs. 9 (3) vs. 0.; upper respiratory tract inflammation 6 (2) vs. 7 (2) vs. 2(2); hot flush 45 (13) vs. 32 (9) vs. 3 (3) SAE, %: 1 vs. 1 vs. 0 (detail NR) Outcome ascertainment: SEP-2, 3; IIEF
Klotz (2001) ^99^ Funding source: NR | N screened = NR N randomized = 25 (cross over) IG1/IG2/CG, n = 25 ITT analysis used for primary outcome: NR Inclusion: men, able to have an erection with visual stimulation; diagnosed with ED as per Cologne Evaluation Form for Erectile Dysfunction (KEED) and IIEF ≤ 6 mo prior to study Exclusion: weak or no response to visual stimulation; no prior response to Sildenafil; ED of neurological or endocrine cause; anatomical abnormality (severe penile fibrosis); SCI, radical prostatectomy, retinitis pigmentosa, DM, any relevant comorbidities (not specified); major psychiatric illness; abnormal BP or heart rate or laboratory tests indicating AV-block] use of nitrites or nitrite oxide donors or user of any medication likely to interact with vardenafil. | Age, mean (sd): 34 (9), range 22–52 y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Initial body weight, mean (sd): 77 (7), range 64–89 kg Broca index: 1 (0.1), range 0.9–1.1 kg | Concomitant medications: NR Duration of ED (yr): NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1/ IG2: Vardenafil oral drinking solution + 20 min VS. (20 min post tx × 3) CG: placebo + 20 min VS. (20 min post tx × 3) IG1/IG2: Dose: 10 mg (IG1); 20 mg (IG2) Duration: N/A Frequency: once Compliance: 100% CG: Placebo Dose: NR Duration: N/A Frequency: once Compliance: 100% Run In period: NR Wash out period: 5 d Fasting overnight and 4 hr post initial dose F/u duration: immediately post tx | Primary outcome (EF): Duration of erection with 60% rigidity: Base: 54 (27) vs. 67 (39) vs. 31 (24) min Tip: 39 (26) vs. 45 (36) vs. 17 (20) min Duration of erection with >80% rigidity Base: 25 (25) vs. 31 (33) vs. 16 (19) min Tip: 9 (13) vs. 22 (30) vs. 7 (14) min Average event rigidity (%): Base: 64 (24) vs. 66 (20) vs. 53 (29) Tip: 47 (27) vs. 45 (23) vs. 32 (26) Circumference, mean (sd): Base= 8 (1); Tip = 7 (1) cm (similar in all 3 grps) Other outcomes assessed: duration of erection; pharmacokinetics; plasma concentration of vardenafil Withdrawals/drop-outs/loss to F/u: 5 (20); 3 not included in safety analysis WDAE: 0 TAE, n (%): 4 (18.2) vs. 2 (9.1) vs. 1 (4.5); including haematoma at the site of sampling IV cannlua; headaches, moderate tiredness, nasal congestion, flush and nasal congestion SAE: 0 Outcome ascertainment: RigiScan (15 s); measuring event rigidity of >20%
Martin-Morales (2006) ^100^ Funding source: Químia Farmacéutica Bayer | N screened = 159 N randomized = 121 (12 centres in Spain) IG, n = 64 CG, n = 65 ITT analysis used for primary outcome: yes (n=61 vs. n=60) Inclusion: men 18–64 y with ED of at least 6 mo duration Exclusion: successful intercourse on more than 50% of attempts during the run in; T value lower than permitted (NR); IC injection of PgE1 in a few days before visit 1 with diagnostic intention; elevated liver enzymes and abnormal ECG | Age, mean (sd): 52.5 (8.6) y (age in severe ED pts 52.8 vs. 52.1 y) Race: White 100% Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status, n (%): past or present smoker 89 (71.2); pack per y hx 44.9 (26.9) vs. 33.7 (21.0), p=0.019 Body weight: 82.6 (12.1) kg BMI, man (sd): kg/m^2^ Other: heavy alcohol consumption in 3 (2.4%) | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): NR Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR ED severity, n (%): by IIEF score, no ED 3 (2.5) Mild 52 (43) Moderate 36 (29.8) Sever 30 (24.8) | IG: Vardenafil CG: Placebo IG: Dose: starting dose 10 mg, adjusted to 5 or 20 mg based on efficacy and tolerability Duration: 12 wks Frequency: NR Compliance: NR CG: Dose: NA Duration: 12 wks Frequency: NR Compliance: NR Run In period: 4 wks Wash out period: NR F/u duration: 12 wks (in addition to 4 wks run in) | Primary outcome results: Change in score from baseline to 12 wks, LS mean (sd): IIEF-EF: 10.9 (6.4) vs. 1.6 (7.7); difference -8.8 [95% CI -11.4; -6.1], p<0.001 IIEF-Q3, mean at 12 wks: 4.6 vs. 3.02 IIEF-Q4, mean at 12 wks: 4.34 vs. 2.69 SEP,% of pts with positive response: SEP-Q2: 64.8% vs. 10.0% SEP-Q3: 62.7% vs. 0.7% GAQ, % improved: 73.8 vs. 25 Other outcomes assessed: individual IIEF question scores Withdrawals/drop-outs/loss to F/u, n (%): 3 (4.7) vs. 5(7.7) WDAE, n (%): NR TAE, n (%): 18 (29.5) vs. 11 (17.2), p=0.138; including headache 8.2% vs. 0, flushing (IG only), nasopharyngitis 4.9% vs. 4.7%, flushing 8.2% vs. 0 SAE, n (%): 1 (1.6) vs. 1 (1.5); one case of intestinal obstruction in IG prior to randomization; non-cardiac chest pain in CG Outcome ascertainment: IIEF-EF; GAQ, SEP, 2–3; Rosenberg Self-Esteem scale, Johnson and McCoy scale Medical Outcome Short Form (SF-36) scale
Mazo (2006) ^101^ Funding source: NR | N screened = NR N randomized = 135 (study also included n=30 healthy men, data not shown) IG, n = NR CG, n = NR ITT analysis used for primary outcome: NR Inclusion: men with ED of at least 6 mo confirmed by pts hx and IIEF-EF domain; tx naïve; in a stable relationship Exclusion: tx with nitrates Note: all pts were examined with Doppler ultrasound of the penile arteries after IC injection of PgE1 | Age, mean (sd): 51 (14.2) Race: NR Co-morbidities, n (%): DM 10 (6); hypertension 48 (29); CAD 20 (12.2), 10% vs. 14.5%; hyperlipidemia 56 (34.2); radical prostatectomy 15 (9) Previous ED treatment: none Smoking status: 27 (32.5) vs. 24 (29.3) Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): no specific cause Psychogenic ED, n (%): 42 (25.5) Physiologic ED, n (%): non-arterial 20 (12.1); arteriogenic 73 (44.3) Mixed ED, n (%): NR | IG: Vardenafil CG: Placebo IG: Dose: 20 mg Duration: NA Frequency: single doese Compliance: 100% CG: Dose: NA Duration: NA Frequency: once Compliance: 100% Run In period: NR Wash out period: NA F/u duration: NA (outcomes measured 1 hr post dosing) | Primary outcome results: No data assessed and reported Other outcomes assessed: % Increase of cavernosal arteries diameter, mean (sd) baseline 51 (26.5) vs. 51.1 (26.7) post tx 71.8 (22.1) vs. 51.6)(27.2) Brachial artery flow mediated dilation: Baseline 9.7 (5.4) vs. 10.6 (5.6) Post tx 13 (4.4) vs. 10.7(5.6); Also reported analysis of outcomes for ED etiology subgroup with greater FMD values in pts with arteriogenic ED, non-sign Withdrawals/drop-outs/loss to F/u, n (%): 0 WDAE, n (%): NR TAE, n (%): NR SAE, n (%): NR Outcome ascertainment: no ED outcome measures used; FMD by Ultrasound
Montorsi, F (2004) ^102^ Funding source: Bayer Corporation, Pharmaceutical Division | N screened = NR N randomized = 732 IG1, n = 237 IG2, n = 248 CG, n = 247 ITT analysis used for primary outcome: yes (ITT: n=708; safety: n=724) Inclusion: men 18 or older, with ED of 6 mo or longer; with 50% or more failure in 4 attempts of intercourse during the run in period Exclusion: penile abnormality; hypoactive SD; uncontrolled DM; radical prostatectomy or malignancy; SCI; chronic haematological, liver dx; retinitis pigmentosa; unstable angina pectoris; atrial tachyarrhythmia; MI, or stroke ≤ 6 mo; use of nitrates, anticoagulants, androgens, anti-androgens, trazodone, selected CYP3A4 inhibitors, alpha blockers/ other ED; hx of unresponsiveness/AE to other PDE5 inhibitors | Age, mean (range): 56 (22–81) y Race, n (%): Caucasian: 603 (83); Black: 22 (3); Hispanic: 13 (2); Asian: 9 (1) Co-morbidities: NR Previous ED treatment, n (%): Sildenafil 521 (72) BMI, mean: 27 kg/m^2^ Smoking status, n (%): 385 (53) Body weight: NR Other: Severity of ED, n (%): Normal (≥26)= 9 (2%); Mild (22–25)= 63 (9%); Mild-moderate (17–21)= 149 (21); Moderate (11–16)= 205 (28); Severe (≤ 10) =280 (39) | Concomitant medications: Drugs acting on renin-angiotensin system: 22% Lipid reducing agents: 17% Calcium channel blockers: 9% Beta-blockers: 9% Duration of ED, mean: 4 y Underlying disease, %: hypertension 30; lipid disorders 17; DM 17; prostatic neoplasms/hypertrophy 13 Psychogenic ED: 310 (43%) Physiologic ED: 118 (16%) Mixed ED: 295 (41%) | IG1: Vardenafil oral IG2: Vardenafil oral CG: Placebo oral IG1: Dose: 10 mg Duration: 4 wks Frequency: 1/d Compliance: NR IG2: Dose: 20 mg Duration: 4 wks Frequency: 1/d Compliance: NR CG: Placebo Dose: NA Duration: 4 wks Frequency: 1/d Compliance: NR Run In period: 4 wks Wash out period: NR F/u duration: 4 wks | Primary outcome results: Onset of adequate erections At ≥ 25 min, (% yes): 50 vs. 53 vs. 26 At 10 min post intake in subgrps, %: Mild/moderate ED: 40 vs. 34 vs. 23 Moderate ED: 21 vs. 20 vs. 10 Severe ED: 6 vs. 12 vs. 8 IIEF, mean (sd) score, IG vs. CG: IIEF- EF: baseline= 13.4 (NR); post tx: 21 (8) vs. 14 (0.6) IIEF-IS: 10 (3) vs. 7 (0.4) IIEF-OS: 7 (3) vs. 5 (0.4) SEP-Q2, % yes: 71 vs. 73 vs. 46 SEP-Q3, % yes: IG 75–77 vs. CG 45–47 Other outcomes assessed: SEP-3 in various time intervals post tx; elapsed time to adequate erection Withdrawals/drop-outs/loss to F/u, n (%): 9 (4) vs. 6 (2) vs. 14 (6) WDAE, n (%): 0 vs. 0 vs. 1 (<1) TAE (%): NR; most common AE in ≥ 2% of pts = headache 7 vs. 12 vs. 1; flushing 6 vs. 9 vs. < 1; nasal congestion 2 vs. 4 vs. < 1; nausea <1 vs. 2 vs. 0; dyspepsia 2 vs. 1 vs. 0; abdominal pain <1 vs. 2 vs. 0 SAE, n: 0 vs. 5 (2) vs. 1 (<1); one patient in IG2 experienced two SAEs; IG included 1 skin ulcer, 1 reflux dx, 1 MI, 1 syncope + encephalitis; CG one pneumonia Outcome ascertainment: IIEF domains; SEP-Q2 and 3
Nagao (2004) ^103^ Funding source: Bayer Yakuhin Ltd | N screened = 375 N randomized = 283 IG1, n = 67 IG2, n = 75 IG3, n = 66 CG, n = 71 ITT analysis used for primary outcome: Yes Inclusion: men 20–70 y, with ED for 6 mo or longer, willing to attempt at least 4 sexual intercourse during 4 wk run-in period, with no sign cardiac dx Exclusion: any medical, psychiatric, substance abuse disorder; any major clinically sign dx or condition; abnormal hormone profile; use of nitrates or nitric oxide donors, beta blockers; erythromycin, ketoconazole, anti-coagulants; antiandrogens, traxodone, investigational drugs in the previous 3 mo; sildenafil or other ED tx within 7 d; hypersensitivity to sildenafil or to ≥ 3 other drugs; unresponsiveness to sildenafil | Age, mean (range): 52 (21–70) y Race (%): all Asian (Japanese) Co-morbidities: NR Previous ED treatment, n (%): Sildenafil IG= 25 (12) vs. CG=4 (6) Smoking status: NR Body weight, mean: 68 kg Other: IIEF-EF Baseline score: mean (sd) 13.7 (5) | Concomitant medications: NR Duration of ED, mean range: 2–3 y Underlying disease: NR Psychogenic ED, n (%): 183 (88) vs. 62 (87) Physiologic ED, n (%): 10 (5) vs. 4 (6) Mixed ED, n (%): 10 (5) vs. 5 (7) | IG1-IG3: Oral vardenafil CG: Placebo IG1-3: Dose: 5 mg (IG1); 10 mg (IG2); 20 mg (IG3) Duration: 12 wks Frequency: as required, no more than once/d Compliance (%): NR CG: Dose: 20 mg Duration: 12 wks Frequency: as required, no more than once/d Compliance (%): NR Run In period: 4 wk unmedicated Wash out period: NR F/u duration: 12 wks, every 4 wks for AE | Primary outcome results: Least square mean IG1-2–3 vs. CG: IIEF Q3: baseline= 3; post: 4.1–4.5–4.6 vs. 3.2 IIEF Q4: baseline = 2; post: 3.5–4.2–4.3 vs. 2.3 IIEF EF: baseline= 13.7; post: 22.4–25.6–25.9 vs. 16.7 GAQ, % yes: 73, 85.3, 86.4 vs. 35.2 Successful intercourse, % yes, baseline vs. tx grp= IG1: 64 vs. 13; IG2: 79 vs. 8; IG3: 80 vs. 10; CG: 33 vs. 9 Other outcomes assessed: Fugl-Meyer quality of life questionnaire Withdrawals/drop-outs/loss to F/u: 7 (10) vs. 9 (12) vs. 6 (9) vs. 15 (21) WDAE, n (%): 2 (3) vs. 2 (2.7) vs. 3 (4.5) vs. 4 (6) TAE, n (%): Per-patient incidence 39 (57) vs. 47 (63) vs. 49 (74) vs. 37 (52); most frequently reported IG vs. CG: flushing 60 (28) vs. 6 (4); headache 21 (10) vs. 6 (4); rhinitis 14 (7) vs. 0 SAE: NR Outcome ascertainment: IIEF- Q3 & 4; GAQ; pts diary of sexual intercourse; Fugl-Meyer quality of life questionnaire
Nehra (2005) ^104^ ^105^ Companion Brock (2003) ^105^ Funding source: Bayer Pharmaceuticals Corp & Bayer Inc. | N screened = 567 N randomized = 440 IG1, n = 146 (ITT, n = 135) IG2, n = 149 (ITT, n = 145) CG, n = 145 (ITT, n = 134) ITT analysis for primary outcome: Yes Inclusion: men 18 or older, with ED due to nerve sparing-radical retro pubic prostatectomy, between 0.5 and 5 y prior to screening; localized tumours allowed; 4 attempts at sexual intercourse on 4 separate d with a 50% or higher chance of failure Exclusion: unstable CV; Gleason tumour score ≥ 8, hx of unresponsiveness to sildenafil due to lack of efficacy or sign. side effects leading to discontinuation, hypoactive SD, low serum T, DM; prostate cancer. | Age, mean: 60 y Race, (%): White 99 vs. 87 vs. 93 Co-morbidities, n (%): depressive disorder1 (<1) vs. 8 (6) vs. 10 (7); acute MI 12 (3); hypertension 130 (30); prostate hyperplasia 11 (3); hypercholesterolemia 91 (21); vasectomy 44 (10) Previous ED treatment, n (%): 338 (77) BMI, mean: 28 kg/m^2^ Smoking status, (%): 46–55% previously smoked Body weight: NR Other: IIEF EF score, mean: pre-operation =23; baseline =9 | Concomitant medications: NR Duration of ED, mean: 1.7 y (post surgery) Underlying disease: nerve sparing radial retro pubic prostatectomy (Mean Gleason tumour=6) Psychogenic ED: NR Physiologic ED: 100% Mixed ED: NR Other: neurovascular bundle sparing: n (% bilateral): 112 (76) vs. 101 (72) vs. 99 (71) | IG1: Oral Vardenafil IG2: Oral Vardenafil CG: placebo IG1/IG2: Dose: 10 mg (IG1), 20 mg (IG2) Duration: 12 wks Frequency: as needed but no more than 1×/day Compliance: NR CG: Dose: NA Duration: 12 wks Frequency: as IG Compliance: NR Run In period: 4 wk tx free Wash out period: NA F/u duration: 12 wks | Primary outcome results: Last observation carried forward, mean IIEF- -Intercourse satisfaction, mean: Baseline, all =5; post tx: 8 vs. 7 vs. 5 IIEF-OF, mean: Baseline, all=5; post tx: 6 vs. 6 vs. 5 IIEF-OS: Baseline, all=5; post tx: 6 vs. 6 vs. 5 Hardness of erection, (mean per pts satisfaction rate %): 28 vs. 24 vs. 8 IIEF-EF score: Baseline, all =9; post tx 15 vs. 15 vs. 9 Mild-moderate ED: 26 vs. 25 vs. 16 Moderate ED: 23 vs. 19 vs. 13 Severe ED: 11 vs. 13 vs. 7 SEP-Q2, mean per pts success rate (%): baseline 21 vs. 18 vs. 14 Post tx: 47 vs. 48 vs. 22 SEP-Q3, mean per pts success rates (%): baseline 7 vs. 7 vs. 6; post tx 37 vs. 34 vs. 10 GAQ, % yes: 59 vs. 65 vs. 13 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: NR WDAE, (%): 4 vs. 3 vs. < 1% TAE, (%): Tx emergent AEs 57 vs. 65 vs. 40; including headache 16 vs. 22 vs. 4; Vasodilation 19 vs. 21 vs. 0; Rhinitis 16 vs. 20 vs. 6; Sinusitis 6 vs. 7 vs. 1; dyspepsia 4 vs. 5 vs. 0; nausea 1 vs. 5 vs. <1 SAE: 1 (<1%) vs. 3 (2%) vs. 1 (<1%) cause NR Outcome ascertainment: IIEF; GAQ; SEP-Q2, and 2
Porst (2001) ^106^ ^107^ Companion study ^107^ Funding source: Bayer | N screened = NR N randomized = 601 (data reported for n=590, pts who took at least one dose of study medication) IG1, n = 147 IG2, n = 141 IG3, n = 150 CG, n = 152 ITT analysis used for primary outcome: Y (n=580) Inclusion: age 21–70 y; in stable heterosexual relationship with ED for at least 6 mo; Exclusion: DM; SCI; radical prostatectomy; sign CAD; hx of hepatitis B and/or C; hypogonadal T levels; thyroid stimulating hormone level <0.28 mU/L; prior nonresponse to sildenafil No other ED tx, or nitrates were permitted Companion study reports on additional analysis in ITT population (n=580), for subgroups of various age and prior sildenafil use | Age, mean (sd): 53 (11) vs. 52 (11) vs. 52 (12) vs. 52 (11) y Race (%): NR Co-morbidities: NR Previous ED treatment, n (%): Sildenafil 74 (51) vs. 67 (50) vs. 72 (49) vs.72 (49) Smoking status: NR Body weight (sd): 83 (16) vs. 85 (14) vs. 84 (14) vs. 85 (15) kg | Concomitant medications: NR Duration of ED, mean (sd): 3 (3) vs. 3 (4) vs. 3 (4) vs. 3 (3) y Underlying disease: NR Psychogenic ED, n (%): 163 (27) Physiologic ED, n (%): 178 (30) Mixed ED, n (%): 245 (41) Other: Severity IIEF domain score, n (%): >25 (none)= 21 (4); 18–25 (mild)= 156 (26); 11–17 (moderate)= 204 (34); <11 (severe)= 195 (32) | IG1-3: vardenafil hydrochloride orally CG: placebo orally IG1-3: Dose: 5 (IG1), 10 (IG2) or 20 (IG3) mg Duration: 12 wk Frequency: once 1 hr before intercourse; max 1/d Compliance: NR CG: Dose: placebo Duration: 12 wk Frequency: as IG Compliance: NR Run In period: 4 wk Wash out period: NA F/u duration: 13 wk Other: 11 (2%) did not take medication | Primary outcome results: Mean change from baseline (sd): IIEF-Q3: 1.2 (1.7) vs. 1.3 (1.5) vs. 1.5 (1.7) vs. 0.2 (1.7) IIEF-Q4: 1.4 (1.7) vs. 1.5 (2.0) vs. 1.7 (2.0) vs. 0.5 (1.7) IIEF- EF: 5.7 vs. 8 vs. 9 vs. 1.6 IIEF-IcS: 2.9 vs. 3.5 vs. 3.6 vs. 1 IIEF-OF: 1.9 vs. 1.6 vs. 1.8 vs. 0 IIEF-OS: 2.1 vs. 2.6 vs. 2.8 vs. 0.8 IIEF-SD: 0.5 vs. 0.4 vs. 0.6 vs. 0 GAQ, % improved: 66 vs. 76 vs. 80 vs. 30, IG vs. CG p<0.001 % of successful intercourse, mean %: baseline: 28.9 vs. 26.1 vs. 24.2 vs. 23.7 post tx: 71.1 vs. 70.9 vs. 74.6 vs. 39.5, IG vs. CG p<0.001 Other outcomes assessed: Fugl-Meyer Quality of Life Questionnaire Withdrawals/drop-outs/loss to f/u: 10 (0.2) WDAE: 7 (5) vs. 2 (1) vs. 1 (0.7) vs. 2 (1) (Not specified) TAE, n (%): pts with one or more AE 40 (27) vs. 38 (27) vs. 62 (41) vs. 14 (9); including headache, flushing, dyspepsia, rhinitis SAE, n (%): 4 (3) vs. 1 (<1) vs. 2 (1) vs. 4 (3) Not specified Outcome ascertainment: IIEF; SEP; GAQ; Fugl-Meyer QoL; pts diary
Porst (2006) ^108^ Funding source: NR | N screened = 483 N randomized = 383 (International 31 centres) IG, n = 194 CG, n = 189 ITT analysis used for primary outcome: yes Inclusion: men 18 or older, with ED > 6 mo IIEF-EF score >5 or lower than 26, who failed on at least 50% of intercourse attempts Exclusion: penile abnormalities; hypoactive sexual dysfunction; surgical prostatectomy; retinitis pigmentosa; hx of hepatitis B surface antigen, hepatitis C, hepatic impairment, haematological disease; MI, stroke or serious arrhythmia in last 6 mo; uncontrolled atrial fibrillation, or DM; hypo/hypertension; heart failure; use of nitrates or nitric acid donors, antiandrogens, androgens, alpha blockers, anticoagulants; vardenafil in last 30 d; ED tx within 7 d | Age, mean (sd): 54.8 (9.3) vs. 56.6 (10.1) y Race: White 75%; Hispanic 11%; Black 8%; Asian 7%; other <1% Co-morbidities, n (%): NR Previous ED treatment, %: sildenafil 33%; tadalafil 28%; vardenafil 10% Smoking status: NR Body weight: NR Other: BMI, mean (sd): 28 (4.7) kg/m^2^ | Concomitant medications, n (%): NR Duration of ED, mean (sd): since diagnosed 4.0 (3.2) vs. 3.9 (3.1) y Underlying disease, n (%): no specific cause Psychogenic ED, n (%): 42 (11) Physiologic ED, n (%): 165 (44) Mixed ED, n (%): 168 (45) Other: -ED severity, n (%): Mild 32 (9) Mild/moderate: 90 (24) Severe 134 (36) -IIEF-EF at baseline, mean (sd): 13.3 (5.5) | IG: Vardenafil CG: Placebo IG: Dose: starting dose 10 mg adjusted to 5, 10, or 20 mg; initial dose of 10 mg, titrated to 5 or 20 mg at wk 2 Duration: 10 wks Frequency: 8 hr before sexual activity Compliance: CG: Dose: NA Duration: 10 wks Frequency: as IG Compliance: Run In period: 4 wks Wash out period: NA F/u duration: 10 wks Other: Dose titration to 20 mg, %: 75 vs. 94 | Primary outcome results: IIEF-EF, LS mean at 10 wks: 22.8 vs. 14.9 Success rate wk 2–6/ wk 0–10, LS mean, %: SEP-2: 81 vs. 51/ 79 vs. 50 SEP-3: 69 vs. 34/ 65 vs. 31 GAQ, %: 77 vs. 27 Other outcomes assessed: EQS superior scores IG vs. CG, p<0.001; primary efficacy data analysed for wk 2–10 (after dose titration) Withdrawals/drop-outs/loss to f/u, n (%): 17 (9) vs. 30 (16) WDAE, n (%): 1 (<1) vs. 1 (<1) TAE, %: pts with any tx emergent AE 39% vs. 22% SAE, n (%): 8 (4) vs. 0; inincluded flushing, headache, hypoaesthesia, hypotension, muscle cramp, arthralgia, back pain, diarrhoea, intervertebral disc protrusion and lethargy Outcome ascertainment: IIEF-EF; GAQ; SEP,2/3;Global Confidence Question (GCQ); Erection Quality Scale (EQS); SEP2, 3
Rosen (2006) ^109^ Funding source: Bayer, and GlaxoSmithKline | N screened = 488 N randomized = 280 IG1, n = 137 CG, n = 143 ITT analysis used for primary outcome: yes (also LOCF) Inclusion: men 18 or older with ED for 6 mo or longer; with diagnosed but untreated mild major depressive disorder; who were not in psychotherapy or taking antidepressants; in a stable heterosexual relationship for more than 6 mo with 50% or more failure rate on at least 4 attempts of sexual intercourse Exclusion: men medically unstable; hx of substance abuse, serious suicidal or homicidal risk, bipolar, schizophrenia, delusional, panic, or personality disorder, posttraumatic stress; penile anatomical abnormalities, primary hypoactive SD; SCI; or prior non-response to sildenafil. | Age, mean (sd); 54 (10) vs. 52 (12) Race, (%): Caucasian 75; Black 8; Asian 2; Hispanic <1; American Indian <1 Co-morbidities: NR Previous ED treatment, %: Sidenafil 59 BMI, mean (sd): 28 (4) vs. 27 (4) kg/m^2^ Smoking status, %: 51 Body weight mean (sd): 85 (15) kg (overweight) | Concomitant medications: None Duration of ED, mean (sd): ≥6mo 3.5 (4) Underlying disease, %: Depression 100; DM 15; vvascular hypertensive 29; elevated cholesterol 12 Psychogenic ED, n (%); 32 (24) vs. 49 (37) Physiologic ED: 25 (19) vs. 15 (11) Mixed ED, n (%): 75 (57) vs. 69 (52) Other, n (%): 12% with elevated cholesterol | IG: Vardenafil CG: Placebo IG1: Dose: 10 mg (titrated to 5 or 20 mg at 4, or 8 wks) Duration: 12 wks Frequency: once/d Compliance, n (%): 118 (86) CG: Dose: NA (titration as IG) Duration: 12 wks Frequency: Once/d Compliance n, (%): 111 (78) Run In period: 4wk Wash out period: None F/u duration (on and off treatment): wk 4, 8 12 | Primary outcome results: IIEF Score, least square mean (LSM): IIEF-EF LS mean improved from baseline: 10 vs. 2, p<0.0001 Intercourse satisfaction: 10.9 vs. 7.8 OF: 7.7 vs. 5.9 OS: 7.1 vs. 4.9 SD: 7.3 vs. 6.4 Erectile hardness: 55.2 vs. 25 SEP-Q2: 76.7 vs. 52.4, p<0.0001 SEP-3: 66.4 vs. 38.1, p<0.0001 GAQ, % improved: (LOCF): 83% vs. 30%; p<0.0001 Other outcomes assessed: Remission of depressive symptoms Withdrawals/drop-outs/loss to f/u, n (%): 10 (7) vs. 29(20); including Insufficient therapeutic effect: 2 (1) vs. 10 (7) WDAE, n (%): 4 (3) vs. 2 (1); reason NR TAE, n (%): NR; AE in at least 2% of pts included headache: 15 (11) vs. 1 (1); flushing: 9 (7) vs. 1 (1); nasal congestion: 4 (3) vs. 0; insomnia: 0 vs. 4 (3) SAE: NR (no death occurred) Outcome ascertainment: IIEF domains, SEP-2/3;GAQ; Hamilton Depression rating scale (HAM-D) score, Rosenberg self-esteem scale.
Stark (2001) ^110^ Funding source: NR | N screened = NR N randomized = 21 (3 way cross over) IG1, n = 21 IG2 randomized = 21 CG randomized = 21 ITT analysis used for primary outcome: NR/ or no Inclusion: men 18–60 y, normal body weight, mild to moderate ED for ≥ 6 mo or longer. Able to respond positively to visual sexual stimuli 4 wks. Exclusion: penile anatomical deformity, SCI, prostatectomy, neurological or endocrine causes of ED, major psychiatric illness, retinitis pigmentosa, DM, extreme hypo or hypertension, medications that might interact with PDE5 inhibitiors (nitrates), intolerance to medications, hypersensitivity and/or allergic reactions, excessive alcohol consumption, past failure to respond to Sildenafil | Age, mean (sd): 45 (10) y Race (%): 100% Caucasian Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight, mean (sd): 83 (10) kg Other: Mean Broca Index = 1 (0.09) | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR: | IG1: oral vardenafil hydrochloride solution IG2: oral vardenafil hydrochloride solution CG: oral placebo solution IG1/ IG2: Dose: 20 mg (IG1); 40 mg (IG2) Duration: 24 hrs Frequency: once Compliance: 100% CG: Dose: NR Duration: 24hrs Frequency: 1× Compliance: 99% Run In period: NR Wash out period: 5 d F/u duration: NR | Primary outcome (EF): Base, % event rigidity, mean (sd): 59 (26) vs. 70 (17) vs. 42 (24) Base, average event tumescence, mean (sd): 10 (4) vs. 11 (3) vs. 8 (4) Tip, % Event rigidity, mean (sd): 50 (24) vs. 58 (19) vs. 34 (23) Tip, average event tumescence, mean (sd): 9 (4) vs. 9 (2) vs. 7 (4) Duration of erections with Rigidity >60% 58 vs. 64 vs. 14 min Mean individual ▴ in duration: 43 vs. 49 vs. NR (IG vs. CG, p <0.001) Duration of erections with Rigidity >80% 30 vs. 40 vs. 6 min pts with at least one erection: 18 (86) vs. 20 (95) vs. 16 (76) Other outcomes assessed: pharmacokinetic results Withdrawals/drop-outs/loss to f/u, n: 3 withdrew and were replaced WDAE: 0 TAE, n (%): 10 (48) vs. 14 (61) vs. 10 (48); including headache, flushing, nasal congestion, visual disturbance (1 event, 35 min post tx with 40 mg), in total 66 AE in 18 (85%) of patients SAE: 0 Outcome ascertainment: RigiScan device, venous blood samples, pts interview/self report
Stief (2004) ^111^ Funding source: Bayer Vital GmbH, Leverkusen | N screened = NR N randomized = 1020 (n=755 completed 1^st^ 12 mo; data provided for n=566 who continued 2^nd^ 12 mo extension period) IG1, n = 272 IG2, n = 294 CG, n = NA ITT analysis used for primary outcome: Yes Inclusion: men 18 or older with ED (NIH Consensus Statement definition) in a steady heterosexual relationship for 6 mo or longer, had to complete the 1^st^ 12-mo tx to be eligible to enter 2^nd^ 12-mo tx period Exclusion: penile abnormalities, primary hypoactive SD, SCI-related ED, retinitis pigmentosa, angina pectoris, uncontrolled DM, resting hypo/hypertension, prior radical prostatectomy, prior use of vardenafil/sildenafil with poor tolerance or unresponsiveness within 6 mo | Age, mean (sd): 55 (22–89) y Race (%): While (91), Black (4), others (5) Co-morbidities: hypertension (33%), diabetes (16%), prostate hyperplasia (18%) Previous ED treatment: Previous viagra use % = 56 vs. 65 BMI, mean (sd): 27 (4) vs. 28 (4) kg/m^2^ Body weight: NR | Concomitant medications: NR Duration of ED, mean (sd): 2 (3) vs. 2 (4) y Underlying disease: NR Psychogenic ED: 17% Physiologic ED: 45% Mixed ED: 36% | IG1: Vardenafil IG2: Vardenafil IG1: Dose: 10 mg Duration: 24 mo Frequency: once/d Compliance: 85% IG2: Dose: 20 mg Duration: 24 mo Frequency: once/d Compliance: 84% Run In period: NR Wash out period: NR F/u duration: 2 y | Primary outcome results: Last observation carried forward (IG1 vs. IG2) IIEF-EF score, mean (sd): Baseline: 13 (5) vs. 14 (6) Post tx: 25 (7) vs. 26 (6) SEP-Q2, mean % with yes response: Baseline: 48 vs. 43; Post tx: 92 vs. 94 SEP-Q3 mean % with yes response: Baseline: 16 vs. 17; Post tx: 87 vs. 89 GAQ, % yes: 90 vs. 92% (sildenafil naïve 90.9 vs. 89.3; Sildenafil experienced 90.1 vs. 93.7) Other outcomes assessed: The Fugl-Meyer Life Satisfaction Checklist items ‘sexual life’ and ‘sexual satisfaction’ Withdrawals/drop-outs/loss to f/u, n (%): 41 (15) vs. 46 (16) WDAE, n (%): 5 (2) vs. 6 (2) TAE, n (%): NR; AEs=headache in 16 vs. 20%; flushing in 14 vs. 20%; rhinitis in 10 vs. 14%; nausea 2 vs. 2%; dyspepsia 4 vs. 9%; sinusitis 1 vs. 2%; conjunctivitis 2 vs. 1%; visual symptoms 5 (2) vs. 8 (3) SAE, n (%): 21 (8) vs. 13 (4); death 1 (0.4) vs. 3 (1) (unknown if the deaths are included in the 34 SAE) Outcome ascertainment: IIEF; SEP question 2, 3, Fugl-Meyer Life Satisfaction Checklist; and CESD scale
Valiquette, (2005) ^112^ ^113^ Funding source: GlaxoSmithKline, King of Prussia, Pa, and Bayer Healthcare Pharmaceutical Division | N screened = 600 (773 originally approached for 4 wk run-in) N randomized = 523 IG1, n = 260 (ITT, n = 255) CG, n = 263 (ITT, n = 254) ITT analysis used for primary outcome: Yes Inclusion: men 18 or older, heterosexual relationship, ED of 6 mo or longer (NIH Consensus Statement), no prior use of Vardenafil. At least 50% of sexual intercourse attempts during the 4 wk run in phase; IIEF-EF score ≤ 26 and ≥5, positive 1^st^ time response to 10 mg challenge. Exclusion: evidence of unstable or chronic medical, psychiatric or substance abuse, penile abnormality, primary hypoactive SD, SCI, hx of radical prostatectomy, retinitis pigmentosa, unstable angina pectoris, hx of MI, stroke or life-threatening arrhythmia in last 6 mo (complete list can be found in full text article) | Age, mean (sd): 53.2 (11) vs. 54.5 (11) y Race (%): White 75; Asian 12; Black 5; Hispanic 4; Other <1 Co-morbidities: Hypertension: 155 (30); DM 72 (14); Benign prostatic hyperplasia 69 (14); Dyslipidemia 82 (16) Previous ED treatment, n (%): sildenafil 337 (64); tadalafil 104 (20) BMI mean (sd): 27 (4) kg/m^2^ Body Weight: NR Other: IIEF-EF score, mean (sd)= 15 (5); severity of ED (%): no attempts (≤5)= 1; severe 23; moderate 35; mild-moderate 30; mild 7; no ED (>25) < 1 | Concomitant medications: NR Duration of ED, mean (sd): 6 (5); range 1–29 vs. 1–41 y Underlying disease: NR Psychogenic ED: n (%): 82 (16) Physiologic ED: n (%): 219 (42) Mixed ED: n (%): 208 (40) | IG: Vardenafil CG: placebo IG: Dose: 10 mg Duration: 12 wks Frequency: as needed, no more than once/ d Compliance: NR CG: Dose: NA Duration: 12 wks Frequency: as IG Compliance: NR Run In period: 4 wk run in period followed by 1 wk open label challenge phase Wash out period: NR F/u duration: 12 wks | Primary outcome results: IIEF-EF score, least square mean (se): 24 (0.4) vs. 16 (0.4) IIEF-EF score equal or more than 26, (% of pts): 50 vs. 16 SEP2-, (% yes): Baseline: 56 vs. 53 Post tx: 83 vs. 56 SEP-Q3, (% yes): Baseline: 22 vs. 21 Post tx: 77 vs. 42 GAQ, (% yes) according to last observation carried forward: 81 vs. 32 Other outcomes assessed: median # of doses/ pts= 32 vs. 20 Withdrawals/drop-outs/lo to f/u, n (%): 76 (30) vs. 43 (17) WDAE, n: 2 (0.8) vs. 4 (2) TAE, n (%): any event 72 (28) vs. 40 (15); including headache 13 (5) vs. 5 (2); flushing 14 (5) vs. 2 (0.8), dyspepsia 6 (2) vs. 1 (0.4) SAE, n: 2 (0.8) vs. 0; facial palsy, appendicitis Outcome ascertainment: SEP, Question 2 and 3; IIEF-EF, and GAQ
van Ahlen (2005) ^114^ Funding source: NR(5/6 authors are employees of Galxo-SmithKline/Bayer producers of vardenafil) | N screened = NR N randomized = 388 (98 primary care sites in Germany) IG, n = 193 (ITT=178) CG, n = 195 (ITT= 176) ITT analysis used: yes (last observation carried forward) Inclusion: men 18 or older with ED of 6 mo or longer; arterial hypertension controlled with 1 or more medication; able to maintain 4 wk ED tx free (at least 4 intercourses) Exclusion: prior use of PED5 inhibitors; penile anatomical abnormalities; hypoactive SD; ED due to SCI or radical prostatectomy; retinitis pigmentosa; hepatitis B, C surface antigen or; unstable angina pectoris; MI, stroke, ischemia; DM; hypotension; use of anticoagulants, androgens, trazodone, antiandrogens, alpha1 antagonist, potent HIV protease inhibitor, nitrates, ketokonazole, erythromycin (more in full text) | Age, mean (range): IG1: mean 56 (range 22–78) y Race (%): NR Co-morbidities: NR Previous ED treatment: NR BMI, mean: 28 vs. 27kg/m^2^ Smoking status: NR Body weight, mean (sd): 88 (14) vs. 86 (12) kg | Concomitant medications, n (%): Antihypertensive medications: Diuretics: 24 (13) vs. 15 (8); Beta-blockers: 81 (42) vs. 82 (43); Calcium channel blockers: 36 (19) vs. 28 (15); Reninangiotensin acting agents: 136 (71) vs. 133 (70) Mean number of antihypertensives per patient: 1.5 vs. 1.4 Duration of ED (yr): NR Underlying disease, (%): Hypertension 100 vs. 99 Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: Vardenafil CG: placebo IG: Dose: starting 10 mg (5 mg in pts 65 or older) one step titration to 5 or 20 mg at 4 & 8 wks Duration: 12 wks Frequency: 1/ d Compliance: NR CG: Dose: NA Duration: 12 wks Frequency: 1/ d Compliance: NR Run In period: 4 wks tx free Wash out period: 4 wks ED tx free F/u duration: 12 wks (4, 8, and 12 wks measures) Other: Allowed a single dose per day (No use of nitrate or concurrent ED therapy ≤ 7 d of study or any investigational drugs < 30 d prior to screening; no use of alpha-blockers permitted) | Primary outcome results: SEP-Q2, % yes: 83 vs. 58, p< 0.0001 SEP- Q3, % yes: 67 vs. 35, p < 0.0001 IEEF-EF, mean score: baseline = 14 vs. 14.5; post tx= 25 vs. 18, p< 0.0001 (unaffected by the class of antihypertensive used) GAQ, % yes: 80 vs. 40, p < 0.0001 Other outcomes assessed: association of tx with clinical measures of BP, or HR Withdrawals/drop-outs/loss to f/u: 34 (8.7) WDAE, n (%): 4 (2) vs. 2 (1) TAE, (%): 21.2% vs. 16.4%; including headache: 6 (3) vs. 1 (0.5); flushing: 3 (2) vs. 1 (0.5) SAE, n (%): 6 (3) vs. 2 (1); no detail provided Outcome ascertainment: IIEF-EF, sum score of Q 1, 5 and 15, SEP question 2 and 3; and GAQ
Ziegler (2006) ^115^ | N screened = NR N randomized = 318 (82 sites in Germany) IG, n = 163 CG, n = 155 ITT analysis used for primary outcome: yes (IG n=153, CG n=149) Inclusion: men 18 or older with ED (by NIH Consensus statement); established DM type I; PDE5i naïve Exclusion: penile abnormalities; hx or SCI, hepatitis B, C; MI; heart or liver conditions (explicitly reported); hypo/hypertension; uncontrolled DM; hx of malignancy within past 5 y or serum creatinine levels > 2.5 mg/dL (pts were prohibited to take nitrates while in the trial); tx with anticoagulant drugs (except anti-platelets); androgens, alpha1-antagonists, potent HIV protease inhibitors, anti mycotic agents itraconazole and ketoconazole, and erythromycin; other ED tx within 7 d of trial entry | Age, mean (sd): 50.3 (9.7) y Race: NR Co-morbidities (%): CV 157 (51.8); nervous system 94 (31); eyes 90 (29.7); endocrine/metabolic 83 (27.4); musculoskeletal system 49 (16.2); urinary tract 46 (15.2); other including allergies 28 (9.3) Previous ED treatment: NR Smoking status: NR Body weight, mean (sd): 85.8 (13.4) kg Other: BMI, mean (sd): 27.2 (3.8) vs. 26.9 (3.4) kg/m^2^ | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): DM Psychogenic ED, n (%): NA Physiologic ED, n (%): all, 100% Mixed ED, n (%): NR Other: Glycemic control, good (HbA_1c_ 7% or less) in 43 vs. 51%; moderate (HbA_1c_ 7–8%) in 58 vs. 47%; poor (HbA_1c_ >8%) 53 vs. 51% | IG: Vardenafil CG: Placebo IG: Dose: flexible dose starting with 10 mg (5 mg for pts 65 or older) titrated to 20 mg Duration: 12 wks Frequency: on demand 1 hr prior to intercourse, up to 1/d Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: 4 wks no tx Wash out period: NA F/u duration: 12 wks Dosing at 12 wks: 87.7% on 20 mg vardenafil; 10.8% on 10 mg, and 1.5% on 5 mg | Primary outcome results: IIEF domains change in score from baseline, mean (sd): EF: 7.79 (7.9) vs. 2.05 (5.8); improvements unaffected by level of glycemic control IcS: 3.43 (3.6) vs. 0.72(2.45) OF: 1.99 (2.6) vs. 0.30 (2.7) SD: 0.67 (1.5) vs. 0.09 (1.4) OS: 2.32 (2.6) vs. 0.52 (2.0) SEP-2, mean % (sd); Baseline: 41 (38) vs. 47 (40) Post tx: 71 (35) vs. 52 (38) SEP-2, mean % (from graph): Baseline: 13 vs. 18 Post tx: 50 vs. 28 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 16 (5.3) with no efficacy evaluation at baseline or post tx WDAE, n (%): 3 (1.8) vs. 2 (1.3) TAE, n (%): 29.4 vs. 20.6; AE in 2% or more pts n= 14 vs. n= 8; headache 5 (3.1) vs. 0; flushing 4 (2.5) vs. 0; bronchitis 3 (1.84) vs. 4 (2.6); nasopharyngitis 2 (1.2) vs. 4 (2.96) SAE, n (%): 7 (4.6) vs. 3 (2), cause NR Outcome ascertainment: IIEF-EF; SEP2, and 3

List of abbreviations: %=percent, ▴=increased, ▾=decreased, AE=adverse event, SAE=serious adverse event, BMI=body mass index, CC=controlled clinical trials, CG=comparator/control group, ctrls=controls, DM=diabetes mellitus, E_1_ IC=intracavernosal injection, ECG=electrocardiograms, ED=erectile dysfunction, EDV=end-diastolic velocity, f/u=follow-up, FMD=flow mediated dilation, GAQ=global assessment question, GEQ=global efficacy question, grp=group/s, HbA1C=haemoglobin, hr=hour(s), hx=history, IG=intervention group, IIEF= international index of erectile function (EF=erectile function, OF=orgasmic function, OS=overall satisfaction, SD=sexual desire), ITT=intent-to-treat (Y = yes, N = no, NR = not reported), IU=intraurethral, kg=kilograms, lbs=pounds, LUTS=lower urinary tract symptoms, M=male, max=maximum, mo=month(s), NA=not applicable, PADAM=partial androgen deficiency of the aging male, PgE_1_=Prostagladin, PRL=prolactin, PSA=prostate-specific antigen, RAU=rigidity activity unit, RCT=randomized control trial, SBP=systolic blood pressure, sign.=significant; TAE=total adverse events, TAU=tumescence activity unit, vs.=versus, WDAE=withdrawals resulting from adverse events, wk=week(s), yr=year(s).

Evidence Table C3. Oral Tadalafil

Author Funding | N; study design; eligibility | Participants characteristics | Diagnosis details | Intervention | Outcomes
Aversa (2007) ^116^ Funding source: NR | N screened = NR N randomized = 20 (22 eligible at level II screening) IG1/IG2, n = 20 CG, n = NA ITT analysis used for primary outcome: yes Inclusion: men 18 y or older with at least 3 mo hx of ED of any severity or etiology Exclusion: tx with nitrates, cancer chemotherapy or anti-androgens; CHF; hyper-homocysteinemia or other conditions or drugs impairing endothelium-dependent vaso-relaxation; (pts with past use of commercially available PDE-5i; and concurrent active drugs were not excluded) Data reported for organic vs. relational vs. Psychogenic pts | Age, mean (sd): 54 (8) y Race: NR Co-morbidities, n (%): hypercholesterolemia 6 (30); DM type II 4 (20); hypertension 4 (20); smoking 4 (20); Psychogenic 2 (10) Previous ED treatment: NR Smoking status, n (%): smokers 4 (20) Body weight: NR Other: BMI, mean (sd) 25.4 (3.6) kg/m^2^ | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): see co-morbidities Psychogenic ED, n (%): 2 (10) Physiologic ED, n (%): 18 (90) Mixed ED, n (%): NR Other: semi structured interview for erectile dysfunction (SIEDY) score, median (quirtile)= organic 3.93 (0–9); relational 2.53 (0–9); Psychogenic 3.33 (0–5) | IG1: Tadalafil on dememand (OD) IG2: Tadalafil on schedule alternated days (AD) IG1: Dose: 20 mg Duration: Frequency: 4 wks Compliance: IG2: Dose: 20 mg Duration: 4 wks Frequency: OD Compliance: Run In period: 4 wks Wash out period: 2 wks F/u duration: 6 time point measurements at baseline and end of each tx period, and 2 wks after last dosing; SIEDY not measured at end point | Primary outcome results: Sexual intercourse/mo: 5.9 (0.4) vs. 6.0 (0.7) N of pills/ mo: 6.0 (1.9) vs. 15.2 (0.6), p<0.05 PSV (cm/s): Baseline: 9.3 (0.3) vs. 9.5 (0.4) Post tx: 10.4 (0.9) vs. 13.2 (0.1) FMD, %, mean (sd) Baseline: 3.3 (0.6) vs. 1.2 (0.6) Post tx: 2.1 (0.9) vs. 8.3 (0.3) Systolic pressure (variation in mmHg): -6.1 (2.2) vs. -4.0 (1.3) Diastolic pressure (variation in mmHg): -3.3 (1.3) vs. -2.3 (1.2) Other outcomes assessed: endothelial markers (VCAM; ICAM; ET-1; CRP; insulin); insulin levels ▴ sign in OD (IG1) compare to IG2 Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): 0 TAE, n (%): 2 (10);headache, back pain, pain and myalgia (no report of abnormal vision or priapism) SAE, n (%): 0 Ascertainment of outcomes assessed: blood flow measures by laboratory analysis; sexual measures by pts logs/interviews
Carrier (2005) ^117^ Funding source: NR (conflict of interest reported as Eli Lilly, or ICOS CO employed some investigators) | N screened = 283 N randomized = 253 IG1, n = 103 IG2, n = 100 CG, n = 50 ITT analysis used for primary outcome: yes, Inclusion: men 18 or older, with at least a 3 mo hx of ED (organic, psychogenic or mix) in a monogamous relationship, and no ED tx for at least 4 wk prior to randomization Exclusion: hx of radical prostatectomy or other pelvic surgery with subsequent failure to achieve erections, presence of clinically sign penile deformity, renal insufficiency, angina, unstable angina in last 6 mo, hx of MI, coronary artery bypass graft surgery or precutaneous coronary intervention within 90 d, HIV, current tx with nitrates, cancer chemotherapy or antiandrogens, or prior non-response to tx with sildenafil | Age, mean (sd): 59 (9) vs. 58 (11) vs. 59(10) y Race: 95% Caucasian Co-morbidities, (%): hypertension 23 vs. 32 vs. 18, arthritis 23 vs. 24 vs. 20; DM 23 vs. 24 vs. 16; allergic reaction 22 vs. 13 vs. 16; prostate dx 19 vs. 16 vs. 26; hypercholesteremia 13 vs. 18 vs. 8; hyperlipidemia 11 vs. 8 vs. 12, back pain 12 vs. 12 vs. 4, hernia 6 vs. 7 vs. 12; headache 7 vs. 5 vs. 10; pain 11 vs. 8 vs. 10 Previous ED treatment, %: sildenafil 68 vs. 54 vs. 62 Smoking status, %: 12 vs. 21 vs. 22 Body weight, mean (sd): 90 (15) vs. 88(10) vs. 84 (12) kg | Concomitant medications: for hypertension CAD, cardiac arrhythmias, congestive heart failure, hyperlipidemia, and DM, n (%)= 101 (98) vs. 28 (56) vs. 62 (62) Note: list of medications is provided in the full text article Duration of ED, n (%): 1 yr or more= 92 (92) vs. 92 (89) vs. 45 (90) Underlying disease, %: prostatic disorder 19 vs. 16 vs. 26 Psychogenic ED: NR Physiologic ED: most commonly present Mixed ED: NR | IG1: Tadalafil IG2: Tadalafil CG: placebo IG1: Dose: 20 mg Duration: 12 wks (three 4 wk periods, Frequency: once /d Compliance: NR IG2: Dose: 10 mg Duration: 12 wks Frequency: once/ d Compliance: NR CG: Dose: NR Duration: same as IG Frequency: same as IG Compliance: NR Run In period: NR Wash out period: NR F/u duration: 12 wk | Primary outcome results: Change in IG1 vs. IG2 vs. CG, mean (SE) IIEF EF domain (1–30): 8 (0.8) vs. 6.6 (0.8) vs. –0.9 (1.1) IIEF intercourse satisfaction (0–15): 3.2 (0.3) vs. 2.2 (0.3) vs. 0.4 (0.4) Successful penetration (SEP-Q2): 21.3 (3.6) vs. 21.3 (3.8) vs. –6.4 (4.1) Successful intercourse (SEP-Q3): 29 (3.7) vs. 32.8 (3.7) vs. 4.9 (4.3) End point Improved erection (GAQ), n (%): 79 (79) vs. 69 (67) vs. 11 (22) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: n=34 (4 vs. 14 vs. 6) Note: pts without both baseline and post-baseline data were excluded from analysis, 3 vs. 4 vs. 1 WDAE: n=5 (IG1 n=3, IG2 n=2) TAE, n (%): AE in >/= 5%=94 (94) vs. 84 (82) vs. 31 (62) (% with dyspepsia: 22 vs. 10 vs. 2; headache: 17 vs. 15 vs. 8; infection: 11 vs. 19 vs. 22; pain: 8 vs. 10 vs. 2; back pain: 7 v. 5 vs. 2; vasodilatation 6 vs. 4 vs. 4; flu syndrome: 5 vs. 8 vs. 10; accidental injury: 5 vs. 1 vs. 4; rhinitis: 4 vs. 6 vs. 4; myalgia 4 vs. 5 vs. 4 SAE: NR Ascertainment of outcomes assessed: IIEF; SEP Q2 & 3 and GAQ
Carson (2005) ^118^ Funding source: Lilly ICOS LLC | N screened = 241 N randomized = 195 IG, n = 146 CG, n = 49 ITT analysis used for primary outcome: Yes Inclusion: men 18 or older, with ED of at least 3-mo duration; in stable heterosexual relationship Exclusion: serious CV condition (e.g. MI, unstable angina, sign.ECG conduction deficit) within 90 days before screening; nitrate tx; congestive heart failure of New York Heart Association Class 2 or above; stroke in previous 6 mo; SBP >100 mm Hg or <90 mm Hg; DBP >100 mm Hg or <50 mm Hg; hx of radical prostatectomy or other pelvic surgery with subsequent failure to achieve an erection; prior ineffective txt with sildenafil | Age, mean (sd): 60 (11) vs. 60 (10) Race (%): White: 119 (82) vs. 43 (88); African descent: 23 (16) vs. 6 (12); Hispanic: 3 (2) vs. 0; Asian: 1 (0.7) vs.0 Co-morbidities, n (%): Coronary artery disease: 15 (10) vs. 0; DM 32 (22) vs. 8 (16); Hyperlipidemia: I52 (36) vs. 19 (39); Hypertension: 59 (40) vs. 21 (43); Prostatic cancer: 17 (11) vs. 4 (8) Previous ED treatment: NR Smoking status: 24 (16.) vs. 8 (16.) Body weight: NR | Concomitant medications: More than one: 126 (86) vs. 40 (82); none 20 (14) vs. 9 (18) Duration of ED, range: 025 or less- 1 y or more [≥0.25 to <0.5 y: 3 (2) vs. 0 ≥0.5 to <1.0 y: 11 (8) vs. 2 (4); ≥1 y: 132 (90) vs. 47 (96) Underlying disease: NR Psychogenic ED, n (%): 4 (3) vs. 2 (4) Physiologic ED, n (%): 119 (82) vs. 41 (84) Mixed ED, n (%): 23 (16) vs. 6 (12) | IG: tadalafil orally CG: placebo orally IG1: Dose: 20 mg Duration: 12 wk Frequency: 1 dose before sexual activity; max. 1/d Compliance: NR CG: Dose: placebo Duration: 12 wk Frequency: 1 dose before sexual activity; max. 1/d Compliance: NR Run In period: 4 wk Wash out period: NA F/u duration: 12 wk | Primary outcome results: IG vs. CG, mean change (SE) IIEF EF: 7 (0.8) vs. –0.2 (1), p<0.001 IIEF -Q3 (ability to penetrate): 1 (0.2) vs. 0.1 (0.3), p <0.001 IIEF-Q4 (maintaining erection): 1 (0.2) vs. 0 (0.2), p < 0.001 Intercourse satisfaction: 3 (0.3) vs. –0.2 (0.5), p <0.001 OS: 2 (0.3) vs. -0.3 (0.3), p<0.001 SEP- Q2 ability to penetrate (% yes): 26 (3) vs. 2 (4.2), p<0.001 SEP-Q3 OS (% yes): 34 (3) vs. 5 (4), p<0.001 Other outcomes assessed: partner SEP2 and 3 Withdrawals/drop-outs/loss to f/u: 48 (IG1 30 [20.5%], CG 18 [36.7%]) WDAE, n: 9 (5.5% vs. 2%) TAE: NR (AEs included headache in 9%, dyspepsia 5%, myalgia 3%; reported mild or moderate in 90% of cases) SAE: 4; 3 (2%, carotid artery bruit, esophageal spasm, brain neoplasm) vs. 1 (2%, angina pectoris) Ascertainment of outcomes assessed: IIEF- SEP; GAQ
Chen, KK (2004) ^119^ Funding source: NR | N screened = 222 N randomized = 196 IG, n = 65 IG2, n = 65 CG, n = 66 ITT analysis used for primary outcome: yes Inclusion: men at least 21 yrs, in a monogamous relationship, at least 3 mo hx of ED of any origin Exclusion: hx of radical prostatectomy or other pelvic surgery with subsequent ED, insufficiency in past 6 mo, hepatobiliary dx, angina occurring during sexual intercourse in last 6 mo, hx of MI, coronary artery bypass graft surgery, or percutaneous coronary intervention within 90 d prior to 1^st^ visit, hx of HIV infection or current infection with any sexually transmitted dx, tx with nitrates, cancer chemotherapy, or anti-androgens, and prior no response to tx with sildenafil citrate | Age, mean (sd): 59 (11.8) vs. 60.4 (11.5) vs. 60.2 (12.9) yr Race (%): NR Co-morbidities, n (%): prostatic dx 20 (31) vs. 25 (39) vs. 25 (38) hypertension 11 (17) vs. 22 (34) vs. 19 (29); CAD (NR); hyperlipidemia 8 (12) vs. 5 (8) vs. 5 (8), and DM 11 (17) vs. 20 (31) vs. 16 (25) Previous ED treatment, n (%): sildenafil 29 (45) vs. 39 (60) vs. 31 (47) Smoking status, n (%): 22 (34) vs. 24 (37) vs. 25 (38) Body weight: NR | Concomitant medications: medication for hypertension (20% vs. 37% vs. 36%), CAD; cardiac arrhythmias; congestive heart failure; hyperlipidemia; DM (14% vs. 25% vs. 18%) Duration of ED, n (%): > 1yr 59 (91) vs. 58 (89) vs. 61 (92) Underlying disease: prostatic disorder; hypertension (17% vs. 34% vs. 29%); DM (17) vs. 31% vs. 24%); hyperlipidemia Psychogenic ED (%): 6 vs. 9 vs. 11 Physiologic ED (%): 71 vs. 69 vs. 65 Mixed ED (%): 23 vs. 22 vs. 24 | IG1: Tadalafil 10 mg IG2: Tadalafil 20 mg CG: Placebo IG1: Dose: 10 mg Duration: 12 wks Frequency: as needed, max 1/d Compliance: NR IG2: Dose: 20 mg Duration: 12 wk Frequency: as needed, max 1/d Compliance: NR CG: Dose: NR Duration: 12 wk Frequency: as needed, max 1/d Compliance: NR Run In period: 4 wks Wash out period: NA F/u duration: 12 wks | Primary outcome results: mean change in score from baseline; overall p value in IG1 vs. IG2 vs. CG: IIEF (1–30): 8 vs. 8 vs. 2.6; p<0.001 [IIEF (intercourse satisfaction domain): sign. ▴ in IG1 and IG2 vs. placebo % of pts with normal IIEF score at end point: 42 vs. 63 vs. 20 SEP (Q2): 34 vs. 35, vs. 10; p<0.001 SEP (Q3): 48, vs. 50, vs. 15; p<0.001 GAQ, % of pts improved erections at endpoint (%): 92 vs. 85 vs. 55 (p<0.001 for overall and pair wise comparison) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): n=13 (7); 4 (6) vs. 3 (5) vs. 6 (9) (personal, sponsor or physician decision to withdraw, n=4 vs. 2 vs. 2) WDAE, n (%): n=3 (1.5): IG2 1 (1.5) elevated serum transaminases vs. CG 2 (3), deafness and MI TAE, n (%): incidence in >/=5%= 37 (57) vs. 46 (71) vs. 29 (44); AE included back pain, dyspepsia, myalgia, infection, rhinitis, dizziness, headache, ▴ cough, arthritis, pharyngitis SAE: NR Ascertainment of outcomes assessed: IIEF at 4, 8 and 12 wks; SEP Q2 & 3 post each intercourse; GAQ at final visit
Choi (2006) ^120^ Funding source: Lilly Research Laboratories | N screened = N randomized = 121(multi center in Korea) IG, n = 80 CG, n = 41 ITT analysis used for primary outcome: yes (LOCF) Inclusion: men 18 or older, in a monogamous relationship, with ED of at least 3 mo in duration; caused by Psychogenic, organic or mixed etiology Exclusion: hx of radical prostatectomy or other pelvic surgery with subsequent failure to achieve erection; sign renal insufficiency within last 6 mo; sign hepatobiliary disease; angina during sexual intercourse in the last 6 mo of study entry; hx of MI or coronary artery bypass graft or precuaneous coronary intervention within 90 d of study entry; HIV | Age, mean (range): 51.4 (24.7–74.4) y Race: 100% Asian Co-morbidities, n (%): benign prostatic hyperplasia 16 (20) vs. 9 (22); DM 16 (20) vs. 5 (12.2); hypertension 12 (15) vs. 5 (12.2); hyperlipidemia 5 (6.3) vs. 4 (9.8) Previous ED treatment: NR Smoking status: NR Body weight, mean: 70.7 kg | Concomitant medications, n (%): NR Duration of ED: NR; pts with ED of at least 1 y 71 (88.8) vs. 39 (95.1) Underlying disease, n (%): no specific condition Psychogenic ED, n (%): 15 (18.8) vs. 10 (24.4) Physiologic ED, n (%): 56 (70) vs. 27 (65.9) Mixed ED, n (%): 9 (11.3) vs. 4 (19.5) Other: ED severity, n (%): Mild 33 (41.3) vs. 17 (41.5) Moderate 33 (41.3) vs. 16 (39) Severe 14 (17.5) vs. 8 (19.5) | IG: Tadalafil CG: Placebo IG: Dose: 20 mg Duration: 12 wks Frequency: on demand, up to once/d (no restriction on food or timing) Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: Run In period: 4 wks Wash out period: F/u duration: | Primary outcome results: Change from baseline, mean: IIEF-EF: 7.8 vs. 0.1, p<0.001 EF by ED severity: Mild 4.8 (n=32) vs. -1.6 (n=17) Moderate 8.6 (32) vs. -0.8 (n=16) Severe 12.7(n=14) vs. 5.3 (n=8) IIEF-Q3: 0.9 vs. -0.2, p<0.001 IIEF-Q4: 1.6 vs. 0.2, <0.001 IIEF-IS: 4.4 vs. 1.5, p<0.001 IIEF-OS: 2.6 vs. 0.7, p<0.001 SEP-2, %: 17.1 vs. 0.5, p<0.001 SEP-3, %: 53.6 vs. 10.1, p<0.001 GAQ-1, %: 80 vs. 43.9 GAQ-2, %6: 80 vs. 43.9 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 6 (7.5) vs. 0 WDAE, n (%): 1 (1.3) vs. 0 TAE, n (%): 38 (47.5) vs. 11 (26.8) Headache, flushing eye pain (only in IG), arthralgia, palpitations, myalgia, pharyngitis, naso-pharyngitis, gastritis somnolence SAE, n (%): 0 Ascertainment of outcomes assessed: IIEF, SEP, GAQ
De Rose (2005) ^121^ Funding source: NR | N screened = 134 N randomized = 120 IG, n = 60 CG, n = 60 ITT analysis used for primary outcome: NR Inclusion: at least 3-mo hx of ED; in a monogamous relationship Exclusion: failure to achieve erection after pelvic surgery; clinically sign. penile deformity; penile implant; stroke within previous 6 mo; spinal cord trauma within previous 6 mo; clinically sign. renal or hepatic insufficiency; treatment with nitrates, antiandrogens or cancer chemotherapy | Age, mean (range): 46 (25–66) vs. 46, (29–63) y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status, n (%): Smoker: 16 (35) vs. 18 (39) Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED, n (%): 5 (10) vs. 6 (13) Physiologic ED, n (%): 24 (52) vs. 22 (48) Mixed ED, n (%): 17 (38) vs. 18 (39) Other: baseline IIEF, n (%): mild 18 (40) vs. 19 (41); moderate 12 (25) vs. 11 (24); severe 17 (35) in both grps | IG1: tadalafil oral CG: placebo oral IG1: Dose: 20 mg Duration: 3 mo Frequency: twice/wk Compliance: 98.3% CG: Dose: placebo Duration: 3 mo Frequency: as IG Compliance: 96.7% Run In period: 4 wk Wash out period: NA F/u duration: 3 mo | Primary outcome results: Mean change in IIEF EF: 12 vs. 3 Mean absolute change in positive response to SEP (%yes) SEP-Q1- (erection): 36 vs. 14 SEP-Q2 (penetration): 34 vs. 12 SEP-Q3 (intercourse completion): 57 vs. 11 SEP-Q4 (hardness of erection): 72 vs. 3 SEP-Q5 (sexual experience): 77 vs. 5 Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u, n: 3 (1 vs. 2) WDAE: 0 TAE, n of pts with at least one AE: 14 vs. 5, included headache 6 vs.3; flushing 4 vs. 0; dyspepsia 2 vs. 2; myalgia and back pain 2 vs. 0 SAE: 0 Ascertainment of outcomes assessed: IIEF, SEP
Eardley (2004) ^122^ Funding source: Lilly ICOS LLC | N screened = 237 N randomized = 220 IG1 screened = NR IG1 randomized = 168 IG2 screened = NA IG2 randomized = NA CG screened = NR CG randomized = 52 Inclusion: age ≥18 yr; at least 3-mo hx of mild to severe ED; in stable heterosexual relationship Exclusion: hx of radical prostatectomy (except for bilateral nerve-sparing) or other pelvic surgery, with subsequent failure to achieve erection; hx of ineffective treatment with sildenafil; unstable cardiovascular disease (e.g. unstable angina, recent myocardial infarction or stroke, poorly controlled hypertension, and New York Heart Association Class II and above congestive heart failure); evidence of clinically sign. renal insufficiency or hepatic insufficiency (e.g. active symptomatic hepatobiliary disease or jaundice); treatment with nitrates, antiandrogens or chemotherapy | Age, mean (sd): IG1 53.6 (range 26–78), CG 52.9 (range 29–73) Race (%): White: IG1 167 (99.4%), CG 52 (100%) Co-morbidities (unrelated to disease): Hypertension: IG1 42 (25.0%), CG 10 (19.2%) Diabetes: IG1 20 (11.9%), CG 5 (9.6%) Alcohol user: IG1 82 (48.8%), CG 30 (57.7%) Blood glucose (or HbA1C)(%): NR Previous ED treatment: Sildenafil: IG1 81 (48.2%), CG 26 (50.0%) BMI (kg/m^2^): NR Smoking status: Smoker: IG1 39 (23.2%), CG 16 (30.8%) Initial body weight: IG1 84.5 kg (range 41–150), CG 83.2 kg (range 60–118) | Concomitant medications: NR Duration of ED (yr): 0.25–0.5: IG1 15 (8.9%), CG 7 (13.5%) 0.5–1: IG1 14 (8.3), CG 7 (13.5%) ≥1: IG1 139 (82.7%), CG 38 (73.1%) Underlying disease (diagnosis) (N or % of diseased/grp): NR Psychogenic ED: IG1 30.4%, CG 26.9% Physiologic ED: IG1 37.5%, CG 32.7% Mixed ED: IG1 32.1%, CG 40.4% Other: Mild ED: IG1 56 (33.3%), CG 16 (30.8%) Moderate ED: IG1 41 (24.4%), CG 13 (25.0%) Severe ED: IG1 68 (40.5%), CG 21 (40.4%) | IG1: tadalafil orally IG2: NA CG: placebo orally IG1: Dose: 20 mg Duration: 12 wk Frequency: as needed (max 1/day) Compliance (%): NR IG2: NA Dose: Duration: Frequency: Compliance (%): CG: Dose: placebo Duration: 12 wk Frequency: as needed (max 1/day) Compliance (%): NR Run In period: 4 wk Wash out period: NA F/u duration (both on and off treatment): 12 wk Other: No | Primary outcome results: Change in EF domain of IIEF and in positive response to questions 2 (“Were you able to insert your penis into your partner's vagina?”) and 3 (“Did your erection last long enough for you to have successful intercourse?”) of Sexual Encounter Profile (SEP) diary Mean change in IIEF EF IG1 11.1 (SD 27.2), CG 0.4 (SD 6.6) Mean absolute change in positive response to SEP Q2: IG1 41.0%, CG 7.3% Q3: IG1 56.5%, CG 10.8% List (narrative) other outcomes assessed: Change in other IIEF domains; positive response to SEP questions 4 and 5; positive response to GAQ (“Has the treatment you have been taking during this study improved your erections?” and “If yes, has the treatment improved your ability to engage in sexual activity?”) AE (in ≥2% of patients in IG1): Headache: IG1 30 (17.9%), CG 3 (5.8%). Dyspepsia: IG1 22 (13.1%), CG 0. Flushing: IG1 8 (4.8%), CG 1 (1.9%). Back pain: IG1 6 (3.6%), CG 0. Pain in limb: IG1 6 (3.6%), CG 0. Myalgia: IG1 4 (2.4%), CG 1 (1.9%). ITT analysis used for primary outcome? Y Withdrawals/drop-outs/loss to f/u [N andor %]: 25 (IG1 16, CG 9) WDAE (N and/or %): IG1 5 (3.0%), CG 1 (1.9%) TAE: NR SAE: IG1 3, CG 1; none judged to be related to study drug Ascertainment of outcomes assessed: NA
Eardley (2005) ^24^ Funding source: Lilly ICOS LLC | N screened = 411 N randomized = 367 IG1, n = 183 (first period) IG2, n = 184 (first period) CG, n = NA ITT analysis used for primary outcome: Yes Inclusion: Pts aged => 18 yrs with documented ED of any aetiology and severity, in a steady relationship with the same female partner naïve to treatment for ED with drugs inhibiting PDE5 Exclusion: Pts with endocrine dx, premature ejaculation, prostatectomy, pelvic surgery, penile deformity, sign renal or hepatic dx, CHF, Within 6 mo, MI, coronary artery bypass surgery, sudden cardiac arrest, sign.arrhythmia, SBP (< 90 – > 170 mmHg) or diastolic (< 50 – > 100 mmHg), malignant hypertension, retinitis pigmentosa, current tx with nitrates, cancer chemotherapy, HIV infection, substance/drug abuse in last 6 mo | Age, mean (sd): 54 (12) y Race (%): Caucasian 92, Black 4, Asian 3, other 1.3 Co-morbidities, (%): hyperlipidemia 11, coronary artery dx 6.5, hypertension 26.4, DM 9.5, depression 4 Previous ED treatment: NR Smoking status, (%): current = 24 Body weight: NR Other: current alcohol use (65%) | Concomitant medications: no other ED treatments Duration of ED: NR (pts with 1 y or more ED =74%) Underlying disease: NR Psychogenic ED: 12% Physiologic ED: 28% Mixed ED: 60% Other: ED defined as consistent change in the quality of erection that adversely affects subject's satisfaction with sexual intercourse Other: Mean IIEF (EF): 14 (6); Severity of ED: severe (IIEF1–10): 31%, moderate (IIEF 11–16): 30%, mild (IIEF 17–30): 39% | IG1: Sildenafil IG2: Tadalafil IG1: Sildenafil Dose: 25–100 mg Duration: 12 wks Frequency: NR Compliance: NR IG2: Tadalafil Dose: 10–20 mg Duration: 12 wks Frequency: NR Compliance: NR Run In period: 4 wks Wash out period: 7–10 d F/u duration: before and after crossover 24 wks (2 periods of 12 wks) Other: Dose was titrated up and down between 25–100 for Sildenafil and 10–20 mg for Tadalafil | Primary outcome results: Mean least squares change from baseline for IIEF domains and 95% CI (IG2 vs. IG1): EF: 0.5 (-0.07, 1.1) OF: 0.3 (0.02, 0.5) SD: 0.2 (0.02, 0.6) Intercourse satisfaction: 0.17 (-0.1, 0.42) Mean change in IIEF questions: erection firmness, intercourse satisfaction and enjoyment, desire level, OS, erection confidence: tadalafil > sildenafil OS: 0.3 (0.02, 0.5) SEP, mean change from baseline: SEP-Q2: 36 vs. 39 SEP-Q3: 53 vs. 58 Other outcomes assessed: mean scores of IIEF, drug preference Withdrawals/drop-outs/loss to f/u: IG1 (1^st^) and IG2 (2^nd^): n=42 IG1 (2^nd^) and IG2 (1^st^): n=39 WDAE: IG1 (1^st^) and IG2 (2^nd^): n=4 IG1 (2^nd^) and IG2 (1^st^): n=7 TAE, n (%): pts with 1 or more AE=125 (34) vs. 128 (35) SAE, n: 4 vs.5 Ascertainment of outcomes assessed: Questionnaires
Govier F (2003) ^123^ Funding source: NR (correspondence: Eli Lillly and Company) | N screened = NR N randomized = 215 (cross over) IG1, n = 109 (Tadalafil - Sildenafil) IG2, n = 106 (Sildenafil - Tadalafil) CG, n = NA ITT analysis used for primary outcome: NR Inclusion: Men with ED for => 3 mo, aged 18–65 yrs, in heterosexual relationship who had never received tadalafil or sildenafil Exclusion: Pts treated with nitrates, recent hx of MI or coronary revascularization, <= 6 mo hx of unstable angina, ED secondary to endocrine disorders, pelvic surgery, stroke or SCI within the last 6 mo, retinitis pigmentosa, HIV infection | Age, mean (sd): 50 (11) y Race (%): White 87, African 9, Hispanic 3 Co-morbidities: NR Previous ED treatment: No tadalafil; sildenafil (15.3%) Smoking status: 23% current smokers Body weight: 90 (19.0) kg Other: height, mean (sd) = 179 (7) cm | Concomitant medications: CVD or diabetes (n = 54) Duration of ED, %: 75% with hx of 1 y or longer Underlying disease: NR Psychogenic ED: 18% Physiologic ED: 39% Mixed ED: 42% Other: severity of ED (based on clinical judgement) = mild (12%), moderate (60%), severe (27.5%) | IG1: tadalafil IG2: sildenafil CG: NA IG1: tadalafil Dose: 20 mg Duration: 4 wks Frequency: once/d Compliance: NR IG2: sildenafil Dose: 50 mg Duration: 4 wks Frequency: once/d Compliance: NR Run In period: 1 wk Wash out period: 1–2 wks F/u duration: 10 wks (per treatment = 4 wks) | Primary outcome (EF): Treatment Preference Question (‘which treatment did you prefer?’) = N (%) pts preferring tadalafil (over sildenafil) vs. N (%) pts preferring sildenafil (over tadalafil) = 126 (66.3%) vs. 64 (33.7%), p < 0.001 Total N of attempts at sexual intercourse = IG1: 2334 vs. IG2: 2233, p = NR Other outcomes assessed: AE Withdrawals/drop-outs/loss to f/u: n=24 (11.2%), n=11 (lost to f/u) WDAE, n: 2 (each pt in IG1 vs. IG2) TAE: NR SAE: NR Ascertainment of outcomes assessed: questionnaires
Guo (2006) ^124^ Funding source: Eli Lilly and Company | N screened = 399 N randomized = 367 IG1, n = 125 IG2, n = 120 CG, n = 122 ITT analysis used for primary outcome: yes Inclusion: men 18 or older in monogamous relationship, at least 3 mo hx of ED, with Psychogenic, organic or mixed cause Exclusion: hx of radical prostatectomy; or other pelvic surgery with subsequent failure to achieve erection; renal insufficiency, hepatobiliary disease, unstable angina within the last 6 mo; hx of MI; coronary artery bypass graft surgery, or precutaneous coronary intervention within 90 d prior to 1^st^ visit; hx of HIV infection; tx with nitrates, cancer chemotherapy, or antiandrogens (discretionary criteria was ineffective tx with sildenafil) | Age, mean (range): 52 (24–82) y Race: East/South-eastern 100% Co-morbidities, n (%): hypertension 77 (21); DM 42 (11.4); benign prostatic hyperplasia 14 (3.8); hyperlipidemia 9 (2.5) Previous ED treatment: NR Smoking status: NR Body weight: NR BMI, mean (range): 24.8 (15.6–50.4) kg/m^2^ | Concomitant medications, n (%): NR Duration of ED: pts with ED of 1 y or longer 341 (92.9) Underlying disease, n (%): no specific cause Psychogenic ED, n (%): 59 (16.1) Physiologic ED, n (%): 107 (29.2) Mixed ED, n (%): 201 (54.8) Other: IIEF severity, n (%) Normal 3 (0.8) Mild 23 (6.3) Mild/moderate 93 (25.3) Moderate 135 (36.8) Sever 113 (30.8) IIEF-EF baseline, mean: 13.6 vs. 13.6 vs. 14 | IG1: Tadalafil low dose IG2: Tadalafil high dose CG: Placebo IG1: Dose: 10 mg Duration: 12 wks Frequency: on demand up to once/d Compliance: NR IG2: Dose: 20 mg Duration: 12 wks Frequency: as IG1 Compliance: NR CG: Dose: NA Duration: 12 wks Frequency: as IG Compliance: NR Run In period: 4 wks Wash out period: NA F/u duration: 12 wks | Primary outcome results: Change in mean from baseline: IIEF-EF: 8.1 vs. 8.7 vs. 2.4 IIEF-Q3: 1.4 vs. 1.5 vs. 0.4 IIEF-Q4: 1.4 vs. 1.6 vs. 0.5 SEP-2, % yes: 33.5 vs. 34.8 vs. 7.7 SEP-3, % yes: 50.0 vs. 56.4 vs. 18.3 GAQ, %: 80.9 vs. 85.7 vs. 43.9 Other outcomes assessed: IIEF-EF based on severity of ED (% of pts in each grp), mean change in score: Mild (31 vs. 28 vs. 34) 24 vs. 23.5 vs. 21.9 Moderate (34.2 vs. 35.2 vs. 37.7) 22.3 vs. 23.0 vs. 15.6 Severe (30 vs. 30.4 vs. 30.2) 18.1 vs. 21.6 vs. 10.7 Withdrawals/drop-outs/loss to f/u, n (%): 10 (8.3) vs. 12 (9.6) vs. 8 (6.6) WDAE, n (%): 2 (1.7) vs. 2 (1.6) vs. 1 (0.8) TAE, n (%): in 2% or more 18 (15) vs. 17 (13.6) vs. 4 (3.3) including headache, back pain, dizziness, dyspepsia, chest pain, cough SAE, n (%): 1 death in IG2 Ascertainment of outcomes assessed: IIEF, GAQ, SEP
Incrocci (2006) ^125^ Funding source: Lilly Icos | N screened = 632 medical records screened; 358 invited N randomized = 60 (cross over trial) IG1/ CG, n = 30/grp depending on the order of tx randomization (IG1 tadalafil first, CG placebo first) ITT analysis used for primary outcome: yes Inclusion: pts with histological proven prostate carcinoma treated by 3DCR at least 12 mo before study Exclusion: excluded prior to surgery: tx with chemotherapy or anti androgens, or hx of metastases; use of nitrates, CVD, coronary artery bypass graft within 90 d of entry, stroke, SCI within 6 mo of entry | Age, mean (range): 69 (53–84) y Race: NR Co-morbidities, n (%): hypertension 17 (28); DM 2 (3); both 3 (5) Previous ED treatment: NR Smoking status: NR Body weight: Other: tumor stages, and differentiation grade PSA, mean (range) 13.9 (1–86) μ/L | Concomitant medications, n (%): Duration of ED: NR (calculated from mean age at radiation-mean age at entry =4 y) Underlying disease, n (%): prostate carcinoma radiation tx Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG: Tadalafil CG: Placebo IG: Dose: 20 mg Duration: 6 wks Frequency: on demand, at least once/wk, up to once/d (no restriction on alcohol or food) Compliance: 100% CG: Dose: NA Duration: as IG Frequency: as IG Compliance: 100% Run In period: 4 wks Wash out period: NR F/u duration: 12 wks; outcomes assessed at end each tx period | Primary outcome results: Mean (sd), tadalafil vs. placebo -IIEF- EF, baseline: 8.4 (3.1): Post tx: 17.7 (9.9) vs. 9.5 (5.9), p -IIEF-OF, baseline: 6.7 (3.0) Post tx: 7.4 (3.1) vs. 4.9 (3.5) -IIEF-SD, baseline: 8.0 (1.9) Post tx: 8.7 (1.7) vs. 7.9 (1.9) -IIEF-IS baseline: 5.9 (1.9) Post tx: 8.2 (3.5) vs. 5.6 (2.3) -IIEF-OS, baseline: 4.3 (2.4) Post tx: 6.5 (3.0) vs. 4.4 (2.6) SEP-2, %: 47 vs. 19, p<0.0001 SEP-3, %: 46 vs. 12 GAQ, %: 67 vs. 20 Successful intercourse, %: 48 vs. 9 Other outcomes assessed: Withdrawals/drop-outs/loss to f/u, n (%): 0 WDAE, n (%): 0 TAE, n: 56 vs. 10 AE included headache, flushing, and dyspepsia sign more in IG; myalgia, nasal congestion, back pain, dizziness not sign between grps SAE, n (%): 0 Ascertainment of outcomes assessed: IIEF, SEP
McMahon (2005) ^126^ Funding source: Lilly ICOS LLC | N screened = 152 N randomized = 140 IG1, n = 93 CG, n = 47 ITT analysis used for primary outcome: Yes Inclusion: ≥18 yr; in monogamous relationship with female partner; at least 3-mo hx of ED Exclusion: premature ejaculation; penile implant; penile deformity; ED due to untreated endocrine condition; radical prostatectomy; pelvic surgery; sign central nervous system injury within 6 mo of screening; clinically sign renal insufficiency within previous 6 mo, hepatobiliary dx or uncontrolled DM; unstable angina; MI, coronary artery bypass grafting or percutaneous coronary arterial intervention within 90 days of screening; prior sildenafil treatment failure (for complete list of exclusions refer to full text article) | Age, mean (sd): IG1 58 (9), CG 61 (7) y Race (%): 98% white in both grps Co-morbidities, n (%): hypertension: 15 (32) vs. 26 (28) hypercholesterolemia: 7 (15) vs. 17 (18) hyperlipidemia: 8 (17) vs. 12 (13) dyspepsia: 6 (13) vs. 12 (13); DM: 8 (17) vs. 9 (10) Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: 1 yr (96% of pts) Underlying disease: NR Psychogenic ED: 2 (4) vs. 10 (11) Physiologic ED: 21 (45) vs. 37 (40) Mixed ED: 24 (51) vs. 46 (50) Other: No | IG: tadalafil orally CG: placebo IG: Dose: 20 mg Duration: 6 mo (24–26 wk) Frequency: 1 dose before sexual activity; max 1/d Compliance: NR CG: Dose: placebo Duration: 6 mo (24–26 wk) Frequency: 1 dose before sexual activity; max 1/d Compliance: NR Run In period: 4 wk Wash out period: NA F/u duration: 24–26 wk + 96 h | Primary outcome results: IG vs. CG, mean change from baseline: IIEF EF: 6.8 vs. 1.6 IIEF- intercourse satisfaction (range 0–15): 2.6 vs. -0.1, p <0.001 IIEF OS (range 2–10): 2.5 vs. 2 GAQ, end point (%): 78 vs. 13 SEP, mean absolute change from baseline in positive response (%): SEP-Q2: 26.5 vs. -7.5 SEP-Q3: 40 vs. 0.9 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 15 vs. 4 WDAE, n: 4 (headache 2, dyspepsia 2) vs. 0 TAE, n of events: 142 vs. 39 (AEs reported: most common) included headache in 40 (43) vs. 4 (9); dyspepsia 20 (22) vs. 0; back pain 15 (16) vs. 7 (15); surgical procedure 15 (16) vs. 8 (17); infection 13 (14) vs. 5 (11); pain 11 (12) vs. 3 (7); accidental injury 10 (11) vs. 7 (15); diarrhea 9 (10) vs. 4 (9); myalgia 9 (10) vs. 1 (2); other included arthralgia, vasodilatation, abdominal pain, cough, flu symptoms, gout, nausea (n of events NR SAE: 0 Ascertainment of outcomes assessed: IIEF- SEP, and GAQ questionnaire
McMahon (2005) ^127^ Funding source: NR | N screened = NR N randomized = 145 (cross over) IG1/IG2, n = 145 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: heterosexual men age 18 or older with ED of 3 mo or longer; with 50% or greater failure rate in maintaining an erection sufficient for completion of sexual intercourse on at least four occasions during the 4 wk run in period Exclusion: penis anatomic abnormalities, hx of radical prostatectomy, ED due to SCI, severe chronic liver dx, renal failure, retinitis pigmentosa, unstable angina pectoris, uncontrolled atrial tachyarrhythmia or any MI, stroke, electrocardiography ischemia or life-threatening cardiac arrhythmia in last 6 mo | Age, mean: 57.6 vs. 57.3 mo Race (%): NR Co-morbidities, n: Diabetes 18 vs. 15, CAD 9 vs. 7; hypertension 22 vs. 21; peripheral vascular disease 4 vs. 2; hyperlipidemia 24 vs. 26; obesity 12 vs. 10 Previous ED treatment, n (%): sildenafil in 94 (65), responders 61 (5) Smoking status, n (%): 43 (30) Body weight: NR | Concomitant medications: NR Duration of ED, mean: 21 vs. 22 mo Underlying disease: NR Psychogenic ED, n (%): 18 (12) Physiologic ED, n (%): 86 (59) Mixed ED: 41 (28) Other: baseline IIEF (ED domain) score, 15 vs. 14; baseline severity of ED in all pts, n (%): mild 23 (16); mild-moderate 33 (23); moderate 56 (39); severe 33 (23) | IG1: Tadalafil 10 mg IG2: Tadalafil 20 mg on demand IG1: Dose: 10 mg Duration: 12 wks Frequency: daily Compliance: NR IG2: Dose: 20 mg Duration: 12 wks Frequency: on demand, 2–3 hrs befoe sexual activity Compliance: NR Run In period: 4 wks Wash out period: 2 wks F/u duration: 12 wks after each intervention regiments | Primary outcome results: IIEF EF domain scores both grps: 26 vs. 23 (p<0.001 vs. baseline, p<0.05 for IG1 vs. IG2) SEP-Q2, mean rate (%): baseline= 36, at 12 wks 73 vs. 85 (p<0.001 vs. baseline, IG1 vs. IG2, p<0.05) SEP-Q3-, mean rate (%): baseline = 30; at 12 wks 80 vs. 67 (p<0.001 vs. baseline, IG1 vs. IG2, p<0.05) Return to normal IIEF score (>26), % of respondents: 73 vs. 57 (p<0.05) GAQ, proportion of yes responses: 88% vs. 73% (p<0.05) Other outcomes assessed: tx preference; severity of AE Withdrawals/drop-outs/loss to f/u: NR WDAE: total n=6 (4%), 4 vs. 2 TAE, n (%): incidence of >2%=35 (24) vs. 41 (28) headache 6 (8) vs. 12 (17); dyspepsia 8 (11) vs. 9 (13); facial flushing 6 (8), vs. 7 (10); nasal congestion 6 (8) vs. 5 (7.1); backache 5 (7) vs. 3 (4); myalgia 3 (4) vs. 3 (4); dizziness 1(1) vs. 2 (3) SAE: n=4 MI, 2 in each tx arms Ascertainment of outcomes assessed: IIEF ED domain; SEP (Q 2 and 3); GAQ
McVary (2007) ^128^ Funding source: Lilly ICOS L.L.C. | N screened = 479 N randomized = 281 (65% ED pts) IG, n = 138 CG, n = 133 ITT analysis used for primary outcome: yes Inclusion: men 45 y or older with hx of LUTS secondary to BPH of 6 mo Exclusion: PSA > 10 ng/ml; hx of any pelvic surgery; neurological condition affecting bladder function; recent LUTS; hx of urethral obstruction; intravesical obstruction 2nd to the prostate median lobe; prostate cancer; PVR 200 ml or more; certain CVD; unstable angina; recent MI; poorly controlled BP or DM; sign renal or hepatic insufficiency; stroke or SCI; use of nitrates, chemotherapy, antiandrogens or potent cytochrome P450 3A4 inhibitor | Age, mean (range): 62 (45–82.4) y Race: White 81%; Black 9.6%; Hispanic 6.8%; Other 2.5 Co-morbidities, n (%): LUTS Previous ED treatment: NR Smoking status: NR Body weight: NR Other: mean baseline I-PSS score post placebo run in=17.9 (range 3–53) | Concomitant medications, n (%): pts agreed not to use any other BPH medication during the study; alpha-blocker tx 24% Duration of ED: reported as pts with ED of 1 y or longer 61.6% vs. 52.1% Underlying disease, n (%): LUTS Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR Note: reported pts with ED: 99 (71.1%) in Tadalafil vs. 84 (59.2%) in placebo | IG: Tadalafil CG: Placebo IG: Dose: 5 mg; titrated to 20 mg at 6 wks Duration: 12 wks Frequency: Compliance: 100% of all pts with data (3% NR) CG: Dose: NA Duration: 12 wks Frequency: as IG Compliance: as IG Run In period: 4 wks single blind placebo Wash out period: NA F/u duration: 16 wks | Primary outcome results: IIEF-EF: Baseline mean: 13.7 vs. 14.3 Change from baseline (post run in), mean (SE) 6 wks: 6.0 (0.9) vs. 0.6 (0.9) 12 wks: 7.7 (0.9) vs. 1.4 (1.0) Other outcomes assessed: change from baseline in I-PSS score, mean (95% CI)= 1.7 (0.5, 2.9) at 6 wks and 2.1 (0.9, 3.3) at 12 wks; more pts in IG improved in this score compare to CG (49% vs. 6.4%, p=0.03) Withdrawals/drop-outs/loss to f/u, n (%): 30 (10.67); 18 (6.8%) in first period, 12 (4.5%) in second period (wk 6–12) WDAE, n (%): 5 (3.6) vs. 2 (1.4) TAE, n (%): NR; AEs were ▴ erection; dyspepsia back pain, headache, naso-pharyngitis, upper respiratory tract infection all more in IG SAE, n (%): 0 vs. 1 (0.7) Ascertainment of outcomes assessed: IIEF-EF; I-PSS; GAQ (post hoc analysis to examine changes at 6 and 12 wks vs. visit 2 before the placebo run in)
Mirone (2005) ^129^ ^130^ Funding source: Lilly ICOS LLC | N screened = 4568 N randomized = 4262 (crossover design) IG1/ IG2, n= 4262 CG, n = NA ITT analysis used for primary outcome: y Inclusion: age ≥18; at least 3-mo hx of ED of any severity or etiology; must have same female partner during study Exclusion: treatment with nitrates, cancer chemotherapy or anti-androgens; symptomatic congestive heart failure | Age, mean (sd): 55 (11) y Race (%): white 97%, African descent 0.7%, western Asian 0.1%, Hispanic 0.1%, east/southeast Asian 0.1%, other 0.2% Co-morbidities: NR Previous ED treatment: another phosphodiesterase type 5, 2513; other ED treatment, 316 Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR pts with < 1 yr 14.8%, ≥1 yr 85.2% Underlying disease (%): cardiovascular dx 32.9; (hypertension in 27), DM 18, hyperlipidemia 12.5, LUTS 9.5, depression 5.2, bilateral-nerve-sparing prostatectomy 3.8 Psychogenic ED: 18.1% Physiologic ED: 34.5% Mixed ED: 47.5% | IG1: tadalafil orally IG2: tadalafil orally IG1: Dose: 20 mg Duration: 5–6 wk Frequency: on demand before sexual activity (max. 1/d) Compliance: NR IG2: Dose: 20 mg Duration: 5–6 wk Frequency: 3 times/wk Compliance: NR Run In period: 3–4 wk Wash out period: 1 wk F/u duration: on treatment: 10–12 wk; after treatment: at least 2 wk Other: n=2108 assigned to on-demand first, followed by set dosage; n=2154 vice versa | Primary outcome results: IIEF, mean score, IG1 vs. IG2: EF: pre=14.3; post: 24.6 vs. 24.8 (% with scores ≥26 =60% vs. 62%) IC s: pre= 6.9; post 11.6 vs. 11.5 OF: pre=2.9; post: 8.3 vs. 8.4 OS: pre= 4.5; post: 7.8 vs. 7.9 SD: pre=6.7; post 7.5 vs. 7.5 SEP (% of pts with positive response): Q1: 68.7; post 91.4 vs. 92.8 Q2: pre=47.8; post: 84.1 vs. 85.6 Q3: pre=21; post: 73 vs. 74 Q4: pre= 6.5; post: 62.9 vs. 65.4 Q5: pre=5.7; post 60.3 vs. 62.8 Other outcomes assessed: Subjects' treatment preference Withdrawals/drop-outs/loss to f/u: 535 WDAE: 4.8% (detail NR) TAE: 926 (22) vs. 1078 (25), AE with at least 2% incidence included headache: 311 (7) vs. 329 (8); dyspepsia: 258 (6) vs. 299 (7); back pain: 110 (3) vs. 125 (3); flushing: 95 (2) vs. 123 (3); myalgia: 88 (2) vs.128 (3); upper abdominal pain: 64 (1) vs. 74 (2); AE in at least 0.4% in extension phase also reported (headache, dyspepsia, back pain) SAE: 0 Ascertainment of outcomes assessed: IIEF, Sexual Encounter Profile (SEP) diary
Montorsi (2004) ^131^ Funding source: Lilly ICOS LLC | N screened = 351 N randomized = 303 IG, n = 201 CG, n = 102 ITT analysis used for primary outcome: Yes Inclusion: bilateral nerve-sparing retro pubic radical prostatectomy 12–48 mo before screening; 65 or younger at time of surgery; postoperative prostate cancer pathological stage pT3 or less; development of ED after surgery Exclusion: ED due to other causes; clinically sign penile deformity; other prior pelvic surgery; penile implant; clinically sign renal or active, symptomatic hepatic dx; uncontrolled diabetes; unstable CV condition; nitrate therapy; detectable PSA level; prior or planned radiation or hormonal therapy for prostate cancer, hx of HIV infection; sign CNS injury | Age, mean (sd): 60 (5) y Race, n (%): White: 186 (93) vs. 95 (93) Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: severity of ED, n (%): Mild 51 (25) vs. 27 (27); moderate 44 (22) vs. 22 (22; severe 106 (23) vs. 53 (52) | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: tadalafil -oral CG: placebo -oral IG1: Dose: 20 mg Duration: 12 wk Frequency: 1 dose before sexual activity (max. 1/d) Compliance: NR CG: Dose: placebo Duration: 12 wk Frequency: 1 dose before sexual activity (max. 1/d) Compliance: NR Run In period: 4 wk Wash out period: NA F/u duration: 12 wk | Primary outcome results: IG vs. CG Change in IIEF EF, mean (SEM): 5 (0.5) vs. 1 (0.6), p<0.001 SEP- Q2, mean (SEM) absolute change in positive response: 22% (2.4) vs. 9% (2.5) SEP- Q3: 23% (2.3) vs. 4% (2.3) GAQ: NR Other outcomes assessed: Mean ED Inventory of Treatment Satisfaction scores; ED outcomes also reported for subgrp of pts Withdrawals/drop-outs/loss to f/u, n (%): 66 (33), n=40 vs. n=26 WDAE, %: 5.5 vs. 2 TAE, n (%): 13 (65) vs. 16 (16); headache 42 (21) vs. 6 (6); dyspepsia 27 (13) vs. 1 (1); myalgia 13 (7) vs. 0; pack pain 9 (5) vs. 6 (6); nasal congestion 9 (5) vs. 1 (1); fatigue 7 (4) vs. 1 (1); flushing 7 (4) vs. 0; sinus congestion 5 (3) vs. 0; cough 4 (2) vs. 1 (1); gastroesophageal reflux dx 4 (2) vs. 0 SAE: 0 Ascertainment of outcomes assessed: IIEF- SEP questionnaire Other: a priori subgrp of n=201 with postoperative penile tumescence 50% or greater positive response to SEP-Q1
Nagao (2006) ^132^ Funding source: Lilly Research Laboratories | N screened = 382 N randomized = 343 (34 Centres in Japan) IG1, n = 85 IG2=IG3, n = 86/ grp CG, n = 86 ITT analysis used for primary outcome: yes (LOCF) Inclusion: men 20 or older with ED of at least 3 mo in duration Exclusion: ED due to primary sexual disorders, hx of radical prostatectomy, pelvic surgery, penile implantation or clinically sign penile deformity; renal insufficiency, HIV infection, CHD, recent hx of MI or coronary artery bypass, malignant hypertension; stroke, angina, or serious arrhythmia, severe hepatobiliary disease; tx with nitrates, alpha-blockers, cancer chemotherapy, or antiandrogens, hx of sign CNS injuries, past unresponsiveness to sildenafil | Age, mean: 55.1 y Race: 100% Asian Co-morbidities, n (%): hypertension 66 (25.7); DM 53 (20.6); benign prostatic hyperplasia 35 (13.6); hyperlipidemia 34 (13.2) Previous ED treatment: sildenafil tx 194 (56.3) Smoking status: 136 (39.7) Body weight, mean: 68.8 kg Other: alcohol consumption 259 (75.5) | Concomitant medications, n (%): NR Duration of ED: pts with ED of at least 1 y 303 (88.3) Underlying disease, n (%): no specific condition Psychogenic ED, n (%): 98 (28.6) Physiologic ED, n (%): 111 (32.4) Mixed ED, n (%): 134 (39.1) Other: ED severity, n (%): Mild 128 (37.3) Moderate 83 (24.2) Severe 132 (38.5) | IG1-3: Tadalafil (various doses) CG: Placebo IG1-3: Dose: 5 mg (IG1), 10 mg (IG2), 20 mg (IG3) Duration: 12 wks Frequency: as needed, up to one tablet/d Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: 4 wks Wash out period: NA F/u duration: 12 wks | Primary outcome results: IIEF-EF, mean baseline score: 13.9 Post tx: 21.0 vs. 23.2 vs. 23.5 vs. 16.0 IIEF-EF, LS mean by ED severity: Mild: 26.6 vs. 26.0 vs. 25.3 vs. 21.1 Moderate: 22.7 vs. 24 vs. 23.0 vs. 15.5 Severe: 15.8 vs. 20.2 vs. 21.9 vs. 11.2 SEP-2 mean % Baseline (from graph): 45 Post tx: 71.2 vs. 81.3 vs. 84.1 vs. 53.6 SEP-3 mean per pts%: Baseline (graph): 15 Post tx: 51.7 vs. 64.6 vs. 69.4 vs. 27.8 GAQ, %: 76.5 vs. 81.4 vs. 83.7 vs. 31.4 Other outcomes assessed: SEP-2/3 post hoc analysis for ED severity grps Withdrawals/drop-outs/loss to f/u, n (%): 8 (9.4) vs. 7 (8) vs. 7 (8) vs. 19 (22); total IG vs. CG 22 (8.6) vs. 19 (22) WDAE, n (%): 3 (1.2) vs. 0 TAE, n (%): pts with 3% or more AE 104 (40.5) vs. 24 (86) Ocular hyperemia 3 (3.5) only in IG3 SAE, n (%): 3 (1.2) vs. 0 including acute prostatitis and pyelonephritis (IG2); mental disorder (IG3); uretral calculus (IG1) Ascertainment of outcomes assessed: IIEF, SEP, GAQ
Porst (2003) ^133^ Funding source: Lilly ICOS LLC | N screened = NR N randomized = 348 IG, n = 175 CG, n = 173 ITT analysis used for primary outcome: Y Inclusion: men 18 or older, minimum 3 mo ED (defined as consistent change in the quality of erection adversely affecting the pts satisfaction with intercourse), in a stable monogamous relationship Exclusion: penile implants or clinically sign penile deformities, failure to achieve erection after radical prostatectomy or pelvis surgery, hx of stroke or spinal cord trauma in the past 6 mo, unstable cardiac disease, and concomitant antiandrogen use or chemotherapy | Age, mean (sd): 57 (NR), range: IG 22–80, CG 28–87 yr Race (%): White 93 vs. 95; African 8 vs. 2; Hispanic 4 vs. 7; other 1 vs. 0 Co-morbidities: NR Previous ED treatment: NR Smoking status: current smoker 25% vs. 23 Body weight: NR Other: alcohol use 57% vs. 61% | Concomitant medications: NR Duration of ED (yr): more than 1 y (in majority of pts) Underlying disease: NR Psychogenic ED, %: 13 vs. 18 Physiologic ED, %: 45 vs. 53 Mixed ED, %: 42% vs. 36% Other: severity of ED (IG vs. CG) mild 70% vs. 69%, moderate 45% vs. 43%, severe 60% vs. 61% (based on erectile domain of IIEF) | IG1: Tadalafil CG: Placebo IG1: Dose: 4 × 20 mg Duration: 8 wks (two 4 wk period, intercourse 24 hrs and 36 hrs after each dose in 1st and 2nd period respectively) Frequency: twice/ 4 wks Compliance: 98% CG: Dose: placebo Duration: same as IG Frequency: same as IG Compliance: 99.5% Run In period: Wash out period: 8–10 d between two doses in each 4 wk period F/u duration: 8 wks | Primary outcome results: Successful intercourse attempts, n (%): 24 hr: 120/227 (53) vs. 72/247 (29.), p<0.001 36 hr: 132/223 (59) vs. 60/212 (28), p<0.001 Patients with successful intercourse attempts, (%): 24 hr: 61 vs. 37, p<0.001 36 hr 64 vs. 35, p<0.001 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: n=21 WDAE, n (%): n=4, 3 (2) vs. 1 (0.5) TAE, n (%): 89 vs. 2; Headache 14 (8) vs. 2 (1), p=0.003, Flushing 10 (6) vs. 0, p=0.002 Dyspepsia 59 (34) vs. 0, p=0.004 Myalgia 6 (3) vs. 0 SAE: 0 Ascertainment of outcomes assessed: Pts self report on Sexual Encounter Profile (SEP-Q3)
Rajfer (2006) ^134^ Funding source: Lilly ICOS LLS. | N screened = 314 N randomized = 287(15 US Centres) IG1, n = 96 IG2, n = 97 CG, n = 94 ITT analysis used for primary outcome: yes Inclusion: men 18 y or older, with ED at least 3 mo in duration caused by psychological, organic or mixed factors Exclusion: ED due to premature ejaculation or untreated endocrine disease, radical prostatectomy or pelvic surgery; penile implant or penile deformity; clinically sign renal or hepatic insufficiency; unstable angina; MI; coronary artery intervention; hx of heart problems; SBP > 170 or <90 mmHg, DBP >100 or <50 mmHg; hx of stroke, SCI; HIV infection | Age, mean (range): 60 (25.5–82.3) y Race: Caucasian 86%; Hispanic 5.6%; African decent 5.6%; Western Asian 1%; Other 1% Co-morbidities, n (%): CAD 30 (10.4); depression 22 (7.6); DM 40 (14); hyper-lipidemia 64(22.3); hypertension 123 (42.8) Previous ED treatment: NR Smoking status: NR Body weight: NR Other: ED severity at baseline, % by IIEF: mild 35%; moderate 26%; sever 39%. | Concomitant medications, n (%): Duration of ED: 96.3% with ED of 12 mo or longer Underlying disease, n (%): NR Psychogenic ED, n (%): 5 (5) vs. 2 (2) vs. 5 (5) Physiologic ED, n (%): 67 (70) vs. 67 (69) vs. 62 (66) Mixed ED, n (%): 24 (25) vs. 28 (29) vs. 27 (29) Other: baseline ED defined as: consistent change in erection quality adversely affecting satisfaction with sexual intercourse) | IG1: Tadalafil low dose IG2: Tadalafil high dose CG: placebo IG1: Dose: 2.5 mg Duration: 24 wks Frequency: once/d Compliance: 94.8%* IG2: Dose: 5 mg Duration: 24 wks Frequency: once/d Compliance: 94.8%* CG: Dose: Duration: 24 wks Frequency: once/d Compliance: 94.8%* Run In period: 4 wks Wash out period: F/u duration: *Note: compliance met if >70% of doses were administered | Primary outcome results: IIEF-EF, mean baseline: 13.4 (1–28) all pts at 24 wks: 19.1 vs. 20.8 vs. 14.6 In mild ED: 24.3 vs. 26.2 vs. 20.8 In moderate ED: 21 vs. 21.9 vs. 14.3 In sever ED: 13.8 vs. 15.5 vs. 8.9 SEP-2, %: All pts at 24 wks: 65.3 vs. 70.7 vs. 51.1 Mild ED: 90.0 vs. 91.9 vs. 79.9 Moderate ED: 74.8 vs. 82.2 vs. 55.7 Severe ED: 38.9 vs. 44.9 vs. 20.1 SEP-3, %: All pts at 24 wks: 50.0 vs. 56.9 vs. 31.3 Mild ED: 72.5 vs. 82.2 vs. 56.7 Moderate ED: 56.3 vs. 61.3 vs. 27.3 Severe ED: 27.4 vs. 32.6 vs. 9.2 GAQ-1, % yes: 62.8 vs. 72.8 vs. 26.1 GAQ-2, % yes: 58.5 vs. 70.7 vs. 23.9 Other outcomes assessed: IIEF, IS domain; IIEF Q3, 4 Withdrawals/drop-outs/loss to f/u, n (%): 15 (15.6) vs. 16 (16.5) vs. 18(19) WDAE, n (%): 6(6.3) vs. 4(4.1) vs. 2(2.1) TAE, n (%): AE occurring in 3% or more 40 (42) vs. 35 (36) vs. 22 (23) SAE: pts with >/=1 SAE 2 vs. 3 vs. 2 including MI, fractures, an road traffic accident Ascertainment of outcomes assessed: IIEF-EF; SEP-2, 3;GAQ; PAIRS
Rodriguez (2006) ^135^ Funding source: NR (medication was not provided to pts) | N screened = NR N randomized = 132 (open label randomized) IG1-6, n = 22 per grp (each grp randomized to particular sequence in which they took the three tx) ITT analysis used for primary outcome: NR Inclusion: men 18 or older, with heterosexual relations, mild to moderate ED of at least 6 mo in duration; naïve to PDE-5i Exclusion: hx of MI; or unstable angina; resting SBP >170 or <90; or DBP >110; retinitis pigmentosa or hx of hepatitis B or C; tx with androgens, cytochrome P-450-3 A4 inhibitors, or alpha blockers | Age, mean (sd): NR Race: NR Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): NR Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG1: sildenafil IG2: vardenafil IG3: tadalafil IG1: Dose: 100 mg Duration: 45–60 d Frequency: at least 6 doses Compliance: NR IG2: Dose: 20 mg Duration: as IG1 Frequency: as IG1 Compliance: NR IG3: Dose: 20 mg Duration: as IG1 Frequency: as IG1 Compliance: NR Run In period: NR Wash out period: 7 d F/u duration: 3 mo (f/u at end of each tx period) | Primary outcome results: IIEF, median (percentile 10–90) Baseline: 17 (11–23) Sildenafil post tx: 29 (25–30) Vardenafil post tx: 28 (23.10–30) Tadalafil post tx: 30 (25–30) (baseline vs. post tx, p<0.0001) Other outcomes assessed: tx preference: Sildenafil 25 (28%) vardenafil 18 (20%) tadalafil 47 (52.22) Withdrawals/drop-outs/loss to f/u, n (%): 42 (31.8) WDAE, n (%): 5 (3.8) vs. 5 (3.8) vs. 2 (1.5) [pts stating they would not continue after study due to AE: 7(5.3%) vs. 2 (1.5%) vs. 4 (3)] TAE: NR AE reported, %: headache 11 vs. 12 vs. 9; flushing 8 vs. 3.3 vs. 4.4; dyspepsia 4.4 vs. 5.5 vs. 2.3; myalgia 0 vs. 0 vs. 4.4; nasal congestion 1.1 vs. 1.1 vs. 2.2; tachycardia 4.4 vs. 1.1 vs. 2.2; vision disorders 4.4 vs. 3.3 vs. 3.3 SAE, n (%): NR Ascertainment of outcomes assessed: IIEF, EDITS
Rosano (2005) ^136^ Funding source: Pfizer | N screened = 49 N randomized = 32 (Parallel double-blinded) IG, n = 16 CG, n = 16 ITT analysis used for primary outcome: NR Inclusion: men aged 59–71 y, with presence of more than 2 risk factors for coronary artery dx (CAD) regardless the degree of their ED; Exclusion: clinically sign findings on physical exam or presence of know clinically sign dx that would prejudice the completion of the study or contraindicate tadalafil assumptions; Recent acute MI, primary valvular, congenital heart dx; myocardial, pericardial or endocardial dx; congestive heart failure | Age, mean (sd): 65 (6) y Race: NR Co-morbidities: NR Blood glucose, mean (sd): sub grp (n=8) with type 2 diabetes 7 (0.5) HbA1C Previous ED treatment: NR BMI (kg/m^2^); mean (sd): 25.4 (3.2) Smoking status, n (%): 10 (31) Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease, n (%): Diabetes: 8 (25) Hypertension: 9 (28) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: only 16 (50%) had presence of ED | IG: Tadalafil (TAD) CG: Placebo IG1: Dose: 20mg Duration: 4 wks Frequency: every other d Compliance: 100% CG: Dose: Duration: 4 wks Frequency: every other d Compliance: 100% Run In period: 4wks Wash out period: None F/u duration: Baseline, end of each treatment, 2 wks after last tx | Primary outcome results: IG vs. CG, mean (sd) GAQ, (yes %) in IG, n=9; CG, n = 7: 8 (88) vs. 1 (14) Brachial artery diameter, baseline to 4 and 6 wks: basal-1, basal 2, nitroglycerine & hyperemia (mm): no sign change from baseline in either grps FMD, %: (sign▴ from baseline in IG only)= 4 (0.6) to 9 (0.3) vs. 4 (0.6) to 4 (0.9) Other outcomes assessed: endothelial marker, mean (sd): Serum nitrogen oxides 38 (12) to 53 (12) vs.36.5 (12) to 39 (8) μmol/l; endothelin-1: sign ▾ from baseline -12% vs. 20% p/ml Nitrite levels, (sign ▴ from baseline in IG only) 38% vs. 7% Withdrawals/drop-outs/loss to f/u: None WDAE: None TAE, n (%): IG, 2 (12) Dyspepsia, headache, back pain, pain, myalgia, spontaneous erection nasal congestion and infection SAE: None Ascertainment of outcomes assessed: GAQ
Rosen (2004) ^137^ Funding source: NR (Eli Lilly and company, and ICOS corporation were involved in editorial and critical review of manuscript) | N screened = NR N randomized = 233 IG, n = 74 IG2, n = 75 CG, n = 74 ITT analysis used for primary outcome: Y Inclusion: heterosexual men age 21 or older, with hx of ED for 3 mo or longer who were not using any other ED therapy during the study Exclusion: ED caused by untreated endocrine disorders, hx of penile implant or sign penile deformities, hx of radical prostatectomy, hepatic, renal, cardiovascular, or central nervous system disorders/injuries, treatment with nitrates, cancer chemotherapy or antiandrogens, current infection with any sexually transmitted disease, hx of drug, alcohol, or substance abuse within the past 6 mo, previous use of tadalafil | Age, mean (sd): 58 (11) vs. 59 (12) vs. 59 (11) yr Race (%): White 87; African decent, 7; Asian, 2; Hispanic, 4 Co-morbidities, n (%): Hypertension, 24 (32) vs. 25 (33) vs. 35 (47) DM, 20 (27) vs. 23 (31) vs. 17 (23) Depression, 5 (67) vs. 11 (15) vs. 5 (7) Hyperlipidemia, 3 (4) vs. 4 (5) vs. 7 (10) Previous ED treatment, n (%): sildenafil 7 (10) vs. 5 (7) vs. 7 (10) Smoking status: NR Body weight, mean (sd): 94 (17) vs. 92 (18) vs. 91 (17) kg | Concomitant medications: NR Duration of ED, n (%): 3 mo or longer: 3 (4) vs. 0 vs. 1 (1) 6 mo or longer: 5 (7) vs. 8 (11) vs. 4 (5) 1 yr or longer: 66 (89) vs. 67 (89) vs. 69 (93) Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: Tadalafil low dose-oral IG2: Tadalafil high dose-oral CG: placebo IG1: Dose: 10 mg (total=292 doses) Duration: 4–5 wks Frequency: 4 doses once every 8–10 d Compliance: NR IG2: Dose: 20 mg (total=300 doses) Duration: as IG1 Frequency: as IG1 Compliance: NR CG: Dose: Placebo (total=284 doses) Duration: as IG Frequency: as IG Compliance: NR Run In period: 28 d no tx Wash out period: NR F/u duration: 30 min after dosing | Primary outcome results: SEP (Q3) yes response (mean %) - at 30 min: 25 vs. 34 vs. 18, (IG1 vs. CG p=0.054, IG2 vs. CG p=0.002) - at 16 min: 9 vs. 47 (16) vs. 22 (8), (IG1 vs. CG p=0.05, IG2 vs. CG 0.012) Other outcomes assessed: minimum time to effect; post hoc analysis for dosing and ED severity Withdrawals/drop-outs/loss to f/u, n (%): 2 (2.7) vs. 1 (1.3) vs. 6 (8.1) WDAE, n (%): 1(1) vs. 1 (1) vs. 2 (3) TAE, n (%): incidence in 11 (15) vs. 13 (17) vs. 1 (1); AE included headache, 3 (4) vs. 6 (8) vs. 0; Myalgia 3 (4) vs. 1 (1) vs. 0; Dyspepsia = nausea = vasodialation1 (1) vs. 2 (3) vs. s0 Back pain, 2 (3) vs. 0 vs. 1 (1) SAE: NR Ascertainment of outcomes assessed: SEP (Q3) and patient diary
Sáenz de TeJada (2002) ^138^ Funding source: Lilly ICOS LLC | N screened = NR N randomized = 216 IG1, n = 73 IG2, n = 72 CG, n = 71 ITT analysis used for primary outcome: yes Inclusion: men 18 or older; clinical diagnosis of type 1 or 2 DM; mild to severe ED for ≥3 mo; in stable monogamous relationship with female partner Exclusion: pts with HbA1C > 13%recent hx of diabetic ketoacidosis; hypoglycaemia requiting assistance; angina during intercourse, unstable angina, dx of coronary artery dx, poorly controlled BP(for complete list of exclusion criteria refer to full text) | Age, mean (sd): 55.7 (9) y Race, n (%): White 215 (99.5); Black 1 (0.5) Co-morbidities, n (%): type I diabetes IG1 = CG 8 (11.3) vs. IG2 4 (5.6); type II DM 65 (89) vs. 68 (94.4) vs. 63 (88.7) Hypertension 80 (37); hypercholesterolemia 38 (18); micro-vascular complications in all grps 48 (22.2) Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, (%): insulin only 36 vs. 28 vs. 45; oral only 44 vs. 54 vs. 41; mix 12 vs. 8 vs. 10 Duration of ED, n (%): > 1y: 201 (93) Underlying disease: diabetes; hypertension Psychogenic ED: NR Physiologic ED: all Mixed ED: NR Other: IIEF score overall, mean (sd)= 12.2 (6.2) Other: subgroup defined based on HbA1C levels: poor (>9.5%)= 40 (18.5), fair (7–9.5%)= 136 (63), good (<7%)= 40 (18.5) | IG1: Tadalafil oral CG: placebo oral IG1: Dose: 10 (IG1) or 20 (IG2) mg Duration: 12 wk Frequency: 1 dose before anticipated sexual activity; max. 1/d Compliance: NR CG: Dose: placebo Duration: 12 wk Frequency: 1 dose before anticipated sexual activity; max. 1/d Compliance: NR Run In period: 4 wk Wash out period: NA F/u duration: 13–14 wk | Primary outcome results: IG1 vs. IG2 vs. CG Change (▴) in mean EF domain of IIEF: 6.4, vs. 7.3 vs. 0.1 (% of pts with more than 5 positive points in IIEF EF domain: 44% vs. 56% vs. 13%, p <0.001) Change (▴) in mean % of “yes” response: SEP-Q2: 22 vs. 23 vs. - 4.1 SEP-Q3: 28 vs. 29 vs. 2 GAQ, proportion of positive responses, (%): 56 vs. 64 vs. 25, p < 0.001 Other outcomes assessed: IIEFQ 3 and 4; OS, and OF (all sign post tx, values NR) Withdrawals/drop-outs/loss to f/u: 25 WDAE: 6 (3%); 5 in IG and 1 in CG; 2 MI one in each grp; moderate myalgia, pain, headache & flushing TAE, n (%): AE in > 3% of pts= 29 (40) vs. 32 (44) vs. 22 (31); dyspepsia 8 (11) vs. 8 (11) vs. 0; headache 9 (10) vs. 6 (8) vs. 2 (3), myalgia 4 (6) vs. 3 (4) vs. 1 (1), flu symptoms, IG=CG 3(4), back pain 1 (1) vs. 4 (6) vs. 1 (1), flushing 2 (3) vs. 3 (4) vs. 0 SAE: 2 (MI) (1 in either grp; however, patient in IG1 never took study drug) Ascertainment of outcomes assessed: IIEF, SEP, GAQ
Saylan (2006) ^139^ Funding source: Lilly ICOS LLC | N screened = 139 N randomized = 132 (Egypt and Turkey) IG, n = 101 CG, n = 31 ITT analysis used for primary outcome: yes (LOCF) Inclusion: men at least 18 y, with ED of at least 3 mo in duration and any kind of severity and etiology Exclusion: ED caused by premature ejaculation or untreated endocrine disease, or after pelvic surgery or pts receiving nitrates, antiandrogens or chemotherapy, sign penile deformity or penile implant, clinically sign renal or hepatic insufficiency, poorly controlled DM; stroke, MI, or SCI, unstable cardiovascular disease; prior ineffective tx with sildenafil (physician discretion) | Age, mean (range): 48.7 (26.6–67.7) vs. 51.7 (27.8–66.1) y Race: Caucasians Co-morbidities, n (%): DM 21 (20.8) vs. 8 (25.8); hypertension 10 (9.9) vs. 7 (22.6); benign prostatic hyperplasia 4 (4.0) vs. 2 (6.5); hypercholesterolaemia 3 (3.0) vs. 1 (3.2); hyperlipidemia 1 (1.0) vs. 2 (6.5) UTI 1 (1.0) vs. 2 (6.5) Previous ED treatment: NR Smoking status: 25.6 vs. 32.3% Body weight: 82.35 kg Other: alcohol consumption <7% | Concomitant medications, n (%): Duration of ED: <6 mo: 14% >/=6 mo: 10 vs. 22.6% >/= 1 y: 75.2 vs. 64.5% Underlying disease, n (%): no specific condition Psychogenic ED, n (%): 11 (10.9) vs. 2 (6.5) Physiologic ED, n (%): 31 (30.7) vs. 9 (29) Mixed ED, n (%): 59 (58.4) vs. 20 (64.5) Other: ED severity, n (%): Mild 35 (34.7) vs. 11 (35.5) Moderate 38 (37.6) vs. 12 (38.7) Sever 28 (27.7) vs. 8 (25.8) | IG: Tadalafil CG: Placebo IG: Dose: 20 mg Duration: 12 wks Frequency: on demand, up to once/d Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: 4 wks Wash out period: NA F/u duration: 12 wks (3 visits) | Primary outcome results: Mean change from baseline (SE): IIEF-EF: 9.3 (0.8) vs. 2.3 (1.6) -By ED severity: Mild: 6.3 (n=32) vs. 0.2 (n=9) Moderate: 8.2 (n=37) vs. 0.3 (n=11) Severe: 14.8 (n=27) vs. 7.5 (n=8) IIEF-Q3: 1.5 (0.2) vs. 0.2 (0.3) IIEF-Q4: 2.0 (0.2) vs. 0.8 (0.3) IIEF-IS: 4.8 (0.3) vs. 2.3 (0.7) IIEF-OS: 3.6 (0.3) vs. 1.1 (0.6) SEP-2, %: 34.5 (4.1) vs. -4.6 (8.1) SEP-3, %: 52.2 (3.8) vs. 16.8 (7.8) GAQ-1, %: 81.2 vs. 41.9 GAQ-2, %: 76.2 vs. 41.9 Other outcomes assessed: SEP Q4–5 Withdrawals/drop-outs/loss to f/u, n (%): 17 (16.8) vs. 6 (19.4) WDAE, n (%): 4 (3.9) vs. 0 TAE, n (%): NR Most commonly reported, %: Headache 16.8 vs. 9.7; back pain 6.9 vs. 0; dyspepsia 2 vs. 6.5 SAE, n (%): 1 (1) vs. 0 (death cardiac arrest in a pts with multiple diseases) Ascertainment of outcomes assessed: IIEF, SEP, GAQ
Seftel (2004) ^140^ Funding source: Lilly ICO LLC | N screened = 239 N randomized = 207 IG1, n = 159 CG, n = 48 ITT analysis used for primary outcome: Yes Inclusion: men 18 or older; at least 3-mo hx of mild to severe ED; stable relationship with female partner Exclusion: clinically sign penile deformity or penile implant; recent hx of stroke of SCI; hx of unstable CV dx in last 90 d; SBP >170 mm Hg or <90 mm Hg, or DPB>100 mm Hg or <50 mm Hg; clinically sign renal or hepatic insufficiency; failure to achieve erection after radical prostatectomy or pelvic surgery; tx with nitrates, antiandrogens or chemotherapy; prior ineffective tx with sildenafil | Age, mean (sd): Race, n (%): White: 151 (73) African descent: 26 (16); 26 (16); Asian: 3 (1); Other: 1 (0.6) Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, n (%): ≥1 y in duration148 (93) vs. 47 (98) Underlying disease: hypertension 75 (36); bbenign prostatic hyperplasia 58 (28); diabetes 36 (17); hyperlipidemia 37 (18); depression 13 (6); CAD 10 (0.5); peripheral vascular disease 1 (2) Psychogenic ED, n (%): 16 (10) vs. 4 (8) Physiologic ED, n (%): 94 (59) vs. 24 (50) Mixed ED, n (%): 49 (31) vs. 20 (42) Other: baseline severity of ED= mild 43 (27) vs. 15 (31); moderate 42 (26) vs. 12 (25); severe 69 (43) vs. 20 (41) | IG: Tadalafil oral CG: placebo oral IG: Dose: 20 mg Duration: 12 wk Frequency: 1 dose before sexual intercourse (max. 1/day) Compliance: NR CG: Dose: placebo Duration: 12 wk Frequency: same as IG Compliance: NR Run In period: 4 wk Wash out period: NA F/u duration: 12 wk | Primary outcome results: Change in IIEF, mean (sd): IIEF-EF: 9.3 (0.6) vs. 0.3 (0.9) Intercourse satisfaction: 4 (0.3) vs. 0.8 (0.4), OS: 3 (0.2) vs. 0 (0.3) Mean (sd) absolute change in positive response: SEP-Q2: 31.6% (2.5) vs. 2% (5.5) SEP-Q3: 43.6% (2.7) vs. 3.5% (4.2) SEP- Q4: 44 (3) vs. 6 (3) GAQ (improved erection), mean (sd) at 12 wk: 125 (83) vs. 9 (20) -Sign improvement in all IG vs. CG, p <0.001 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 31 (23 vs. 8) WDAE: 9; 8 (5.0%) vs. 1 (2) TAE: NR (AE (%)=headache: 16 vs. 6; back pain: 9 vs. 0; dyspepsia 8 vs. 0) SAE, n: 2 (chest pain) vs. 0 Ascertainment of outcomes assessed: IIEF- SEP (Q2 and 3)
Skoumal (2004) ^141^ Funding source: Eli Lilly and Company | N screened = NR N randomized = 409 IG1, n = 305 CG, n = 104 ITT analysis used for primary outcome: Yes Inclusion: men 18 or older, with at least 3-mo hx of mild to severe ED; same female partner throughout study Exclusion: ED due to premature ejaculation or untreated endocrine dx; failure to achieve erection after pelvic surgery, including radical prostatectomy (except bilateral nerve-sparing); sign penile deformity or penile implant; clinically sign renal or hepatic insufficiency; poorly controlled diabetes; unstable CA dx; recent hx of sign CNS injury; hx of HIV infection; exclusion of pts with prior ineffective tx with sildenafil was at discretion of investigators | Age, mean (95% confidence interval): 52 (51–53) vs. 52 (49–54) y Race (%): NR Co-morbidities, n (%): hypertension 98 (32) vs. 31 (30); Diabetes 43 (14) vs. 9 (9); Prostatic hyperplasia/ hypertrophy 19 (6) vs. 11 (11); hypercholesterolemia 31 (10) vs. 9 (9); hyperlipidemia: 16 (5) vs. 3 (3) Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: less than 0.25 y - equal or more than 1 y (majority, 78 vs. 80% with 1 y or longer) Underlying disease: NR Psychogenic ED, n (%): 46 (15) vs. 19 (18) Physiologic ED, n (%): 89 (29) vs. 29 (28) Mixed ED, n (%): 170 (56) vs. 56 (54) Other: baseline IIEF EF severity class, n (%)= mild 145 (48) vs. 49 (47); moderate 89 (29) vs. 31 (30); severe 71 (23) vs. 24 (23) | IG1: Tadalafil (Cialis^(R)^) oral CG: placebo- oral IG1: Dose: 20 mg Duration: 12 wk Frequency: as needed (max. 1/day) Compliance (%): NR CG: Dose: placebo Duration: 12 wk Frequency: as needed (max. 1/day) Compliance (%): NR Run In period: 4 wk Wash out period: NA F/u duration: 12 wk | Primary outcome results: Mean change in IIEF score (and 95% confidence interval) EF: 10 (9–10.6) vs.1.4 (0.1–2.8) Intercourse satisfaction: 5 (4.4–5.1) vs. 1.4 (0.8–2.1) OF: 2 (1.9–2.6) vs. 0.2 (-0.4–0.8) SD: 1 (0.9–1.3) vs. 0 (-0.3–0.4) OS: 4 (3.4–4.0) vs. 0.7 (0.2–1.2) Mean absolute change SEP-Q2 (yes): approx. 2% vs. 35% SEP-Q3: IG1 approx. 53%, CG approx. 13% GAQ-1: 86% vs. 33% GAQ-2: 97% vs. 94% Other outcomes assessed: ED Inventory of Treatment Satisfaction scores Withdrawals/drop-outs/loss to f/u, n (%): 23 (6) WDAE: 1 vs. 0 TAE, n (%): >/= 2 events= 55 (18) vs. 3 (3); headache, back pain in 10 vs. 3%; flushing, influenza, and nasal congestion only in IG (9%) SAE: 2 (pulmonary embolism, subarachnoid hemorrhage) vs. 0 Ascertainment of outcomes assessed: IIEF ED domain, SEP (Q2, and 3); GAQ
Staab (2004) ^142^ Funding source: Eli Lilly and Company | N screened = NR N randomized = 212 IG, n = 171 (2 mg =42, 5 mg= 44, 10 mg= 42, 25 mg =43) CG, n= 41 ITT analysis used for primary outcome: NR Inclusion: men18 or older; with ED for 3 mo or longer; in stable, monogamous, heterosexual relationship Exclusion: ED due to untreated endocrine disorder; hx of radical prostatectomy, with failure to achieve any erection; pelvic surgery; sign penile curvature; prior unsuccessful tx with phosphodiesterase type 5 inhibitors; hx of human immunodeficiency virus infection; poorly controlled diabetes; clinically sign hepatic, renal, cardiovascular or central nervous system dx during prior 6 mo | Age, mean (sd): 58 (10) y Race, n (%): White 194 (92), African descent 10 (5), Asian 7 (3), other 1 (0.5) Co-morbidities, n (%): currently active cardiovascular condition 85 (40), hx of cardiovascular condition 8 (4), diabetes 44 (21) Previous ED treatment: NR Smoking status, n (%): Current smoker 40 (19) Body weight, mean (sd): 87 (14.5) kg | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: ED severity: mild 93 (44%); moderate 52 (25%); severe 67 (31%); no sign difference between IG | IG1: tadalafil -oral CG: placebo -oral IG1: Dose: 2, 5, 10 or 25 mg Duration: 8 wk Frequency: max. 1/day (1 dose before sexual intercourse) Compliance: NR CG: Dose: placebo Duration: 8 wk Frequency: as IG Compliance: NR Run In period: 4 wk Wash out period: NA F/u duration: 8 wk | Primary outcome results: IG (only reported for 25 mg grp) vs. CG: IIEF Q3, approximate % with score of 5: 75% vs. 20% IIEF Q4, approximate % with score of 5: 62% vs. 10% IIEF EF, mean score: 24 vs. 14 SEP Q3 - % positive response: 82% vs. 52% SEP Q4 - % positive response: 78% vs. 40% Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n: 10 WDAE, n: 2 TAE: NR SAE: NR Ascertainment of outcomes assessed: IIEF questions 3 and 4: scored from 0 (no intercourse) to 5 (best performance) IIEF EF domain: sum of scores for questions 1–5 and 15 Other: results are shown in probability tables
Von Keitz (2004) ^143^ Funding source: Lilly ICOS LLC | N screened = 299 N randomized = 219 (cross over drug preference) IG1, n = 105 IG2, n = 114 CG, n = NA ITT analysis used for primary outcome: No Inclusion: men 18–65, with ED for at least3 mo (consistent change in the quality of erection hat adversely affected the patient's satisfaction with sexual intercourse), in heterosexual relationship; also pts non-responsive to previous tx with sildenafil Exclusion: Pts treated with nitrates, recent hx of MI or coronary revascularization (within 90 d), rapid ejaculation, 6 mo or longer hx of unstable angina, ED secondary to endocrine disorders, pelvic surgery, stroke or SCI within the last 6 mo, retinitis pigmentosa, HIV infection | Age, mean (sd): 52.5 (9.3) y Race (%): White 89, African 7, Hispanic 2, Asian 2 Co-morbidities, (%): hypertension 26, DM 17, depression 4, CAD 3 Previous ED treatment: sildenafil (66%) Smoking status, (%): current smokers= 29 Body weight: NR | Concomitant medications: CVD or diabetes (n = 54) Duration of ED (yr): => 1 yr (94%) Underlying disease: NR Psychogenic ED: 7% Physiologic ED: 42% Mixed ED: 51% Other: severity of ED (based on clinical judgement; %) = mild (18%), moderate (56%), severe (26%) | IG1: Tadalafil+ Tadalafil instruction 1^st^; Sildenafil + sildenafil instruction 2^nd^ IG2: Sildenafil+ Sildenafil instruction 1^st^; Tadalafil + Sildenafil instruction 2^nd^ IG1: Dose: 20 mg Duration: 12 wks/ period Frequency: once/d Compliance: NR IG2: Dose: 50 mg Duration: 12 wks/period Frequency: once/d Compliance: NR Run In period: 1 wk Wash out period: 1–2 wks (1^st^ washout), 96 hrs 92^nd^ washout post 24 wks prior to 12 wks extension period) F/u duration: 38 wks (2 ×12 wks tx + 1–2 wks washout + 96 hrs no tx at end +12 wks extension Other: preference of dosing instructions also in two additional arms (n=36) | Primary outcome (EF): No ED outcomes reported N (%) pts preferring tadalafil (over sildenafil) vs. N (%) pts preferring sildenafil (over tadalafil) = 132 (73) vs. 49 (27), p < 0.001 Other outcomes assessed: treatment preference by subgroups, AE Withdrawals/drop-outs/loss to f/u, n (%): 24 (23) vs. 28 (25); including total withdrawals17 (16) vs. 21 (18); lost to f/u 7 (7) vs. 7 (6) WDAE, n (%): 4 (4) vs. 3 (3) TAE, n (%): pts with 2 or more AE= 73 (70) vs. 57 (50); AE included headache 26 (12) vs. 17 (8); dyspepsia 14 (6) vs. 10 (5); back pain 9 (4) vs. 4 (2); myalgia 9 (4) vs. 1 (0.5); flushing 6 (3) vs. 8 (4); nasal congestion 6 (3) vs. 10 (5); influenza-like illness 3 (1) vs. 7 (3) SAE: NR Ascertainment of outcomes assessed: questionnaires to determine pts preference of tx
Yip (2006) ^144^ Funding source: Lilly Research Laboratories | N screened = N randomized = 242 (17 centres across China) IG1, n = 159 CG, n = 83 ITT analysis used for primary outcome: NR Inclusion: men 18 or older with ED of at least 3 mo in duration of Psychogenic, organic or mixed causes Exclusion: ED caused by premature ejaculation, or untreated endocrine disease; pelvic surgery, including radical prostatectomy; penile deformity, or penile implant, renal or hepatic insufficiency, uncontrolled DM, unstable CVD, hx of central nervous system injury, HIV infection (discretionary criteria: prior ineffective tx with sildenafil) | Age, mean (range): 54 (28–78) y Race: East/Southeast Asian 97% Co-morbidities, n (%): DM 31%; hypertension 30%; benign prostatic hyperplasia 22.9% vs. 17.6; hypercholeserolemia 6% vs. 11% Previous ED treatment: NR Smoking status: NR Body weight: 70.3 (9.4) vs.68.6 (9.5) kg | Concomitant medications, n (%): NR Duration of ED: pts with ED longer than 1 y, n (%) 131 (82.4) vs. 76 (91.6) Underlying disease, n (%): NR Psychogenic ED, n (%): 22 (13.8) vs. 19 (22.9) Physiologic ED, n (%): 94 (59.1) vs. 54 (65.1) Mixed ED, n (%): 43 (27) vs. 10 (12) ED severity, n (%): severe 26%; moderate 33%; mild 41% Baseline IIEF-EF, mean: 14.9 vs. 14.8 | IG: Tadalafil CG: placebo IG1: Dose: 20 mg Duration: 12 wks Frequency: on demand, up to once/d Compliance: NR CG: Dose: NA Duration: 12 wks Frequency: on demand, up to once/d Compliance: Run In period: 4 wks Wash out period: NA F/u duration: 12 wks | Primary outcome results: Change in mean from baseline: IIEF-EF: 8.5 vs. 2.1, P<0.001 IIEF-Q3: 1.3 vs. 0.2, P<0.001 IIEF-Q4: 1.7 vs. 0.5, P<0.001 SEP-2, % yes: 30.1 vs. -1.2, P<0.001 SEP-3, % yes: 46.7 vs. 8.9, P<0.001 GAQ-1, % improved: 86.2 vs. 30.1 GAQ-2, % improved: 80.5 vs. 28.9 Other outcomes assessed: IIEF-EF based on severity of ED (% of pts in each grp), mean change in score: Mild (39% vs. 42%) 5.3 vs. -0.3 Moderate (35% vs. 30) 9.1 vs. 2.7 Severe (25.8% vs. 26.5%) 12.5 vs. 5.2 Withdrawals/drop-outs/loss to f/u, n (%): 12 (5) [5 (3) vs. 7 (8)] WDAE, n (%): 2 (<1) vs. 1 (<1) TAE, n (%): AE in 3% or more46 (28.9) vs. 6 (7.2); included headache, back pain, dizziness, dyspepsia, and myalgia SAE, n (%): 3 (1.8) vs. 1 (1.2) including a worsening of CAD, fractures and dengue fever in IG; DM & sepsis in CG Ascertainment of outcomes assessed: IIEF, GAQ, SEP
Young (2005) ^145^ Funding source: Lilly ICOS LLC (Bothell, Wash and Indianapolis) | N screened = NR N randomized = 483 (phase III) IG1, n = 161 IG2, n = 161 CC, n = 161 Note: pts further sub-divided for efficacy analyses at 24 hr post dosing (n= 80) & 36 hr (n= 81) for all grps ITT analysis used for primary outcome: y Inclusion: at least 18 y of age, reported minimum of 3 mo hx of ED Exclusion: clinically sign. penile deformities or penile implants, a recent hx of stroke or spinal cord trauma, unstable cardiovascular status (e.g. unstable angina, myocardial infarction, or myocardial revascularization within 90 days), use of nitrates, cancer chemotherapy, or antiandrogens, failure to achieve erection following radical prostatectomy or pelvic surgery. | Age, mean (range): 57.4 (33–82) vs.58 (26–75) vs. 58(37–78) y Race (%): Caucasian 80 vs. 87 vs. 83; African descent 10 vs. 8 vs. 14; Hispanic 8 vs. 5 vs. 2; other 2 vs. 0.6 vs. 2 Co-morbidities, (%): DM 8 (11) vs. 11 (7) vs.15 (9); hypertension 64 (40) vs. 64(40) vs. 60 (37); coronary artery disease 5 (3) vs. 8(5) vs. (5) Previous ED treatment: NR Smoking status, n (%): current smoker 27(17) vs. 26 (16) vs. 21(13) Body weight: NR | Concomitant medications: testosterone (total = 22 pts) during post baseline period Duration of ED: 3 mo Underlying disease: NR Psychogenic ED, n (%): 16 (10) vs. 14 (9) vs.16 (10) Organic ED, n (%): 109 (68) vs. 115 (71) vs.100 (62) Mixed ED, n (%): 36 (22) vs. 32 (20) vs. 45 (28) | IG: tadalafil, 10 mg, oral IG2: tadalafil, 20 mg, oral CG: oral placebo IG Dose: 10 mg Duration: 4–6 wks Frequency: 4 diff. times at 24 or 36 hrs post dosing, 7 d between each dose Compliance: NR IG2 Dose: 20 mg Duration: 4–6 wks Frequency: as IG1 Compliance: NR CG: Dose: placebo Duration: 4–6 wks Frequency: as IG Compliance: NR Run in period: 4 wks + 2–4 wks equilibration phase Wash out period: 7 d F/u duration: 4–6 wks for efficacy (6 mos open-label active medication extension - results NR) | Primary outcome results: SEP3, mean per pt % “yes” responses, % change): 24-hrs IG (55.8%, ▴ 25.5%, p = 0.038), IG2 (67.3%, ▴ 46.3%, p < 0.001) sign superior vs. CG (41.8%, ▴9.4%) 36-hrs IG (56.2%, ▴ 23.9%, p< 0.001), IG2 (61.9%, ▴28.7%, p<0.001) sign successful vs. CG (32.8%, ▴1.9%) Other outcomes assessed: SEP-Q1, 2,4,5 Withdrawals/drop-outs/loss to f/u, n (%): 23 (4.8%) WDAE (%): IG= 2, vs. CG= 0.6 TAE n (%): AE in 2% or more= 37 (23) vs. 55 (34) vs. 9 (5.6); AE included headache 9 (6) vs. 17 (11) vs. 1 (0.6); back pain 11 (7) vs. 10 (6) vs. 1 (1); dyspepsia 6 (4) vs. 8 (5) vs. 1 (0.6); nasopharyngitis 8 (5) vs. 5 (3) vs. 5 (3); nasal congestion 3 (2) vs. 6 (4) vs. 0; upper respiratory tract infection 4 (3) vs. 5 (3) vs. 3 (2); myalgia 2 (1) vs. 5 (3) vs. 0; influenza 2(1) vs. 4 (3) vs. 3 (2). SAE: n=3, 1 death in IG2; 2 (NR) in CG Ascertainment of outcomes assessed: SEP3: “Did your erection last long enough for you to have successful intercourse?” [yes/no]

List of abbreviations: %=percent, ▴=increased, ▾=decreased, AE=adverse event, SAE=serious adverse event, BMI=body mass index, CC=controlled clinical trials, CG=comparator/control group, ctrls=controls, DM=diabetes mellitus, E_1_ IC=intracavernosal injection, ECG=electrocardiograms, ED=erectile dysfunction, EDV=end-diastolic velocity, f/u=follow-up, FMD=flow mediated dilation, GAQ=global assessment question, GEQ=global efficacy question, grp=group/s, HbA1C=haemoglobin, hr=hour(s), hx=history, IG=intervention group, IIEF= international index of erectile function (EF=erectile function, OF=orgasmic function, OS=overall satisfaction, SD=sexual desire), ITT=intent-to-treat (Y = yes, N = no, NR = not reported), IU=intraurethral, kg=kilograms, lbs=pounds, LUTS=lower urinary tract symptoms, M=male, max=maximum, mo=month(s), NA=not applicable, PADAM=partial androgen deficiency of the aging male, PgE_1_=Prostagladin, PRL=prolactin, PSA=prostate-specific antigen, RAU=rigidity activity unit, RCT=randomized control trial, SBP=systolic blood pressure, sign.=significant; TAE=total adverse events, TAU=tumescence activity unit, vs.=versus, WDAE=withdrawals resulting from adverse events, wk=week(s), yr=year(s).

Evidence Table F4. Apomorphine (sublingual)

Author Funding | N; study design; eligibility | Participants characteristics | Diagnosis details | Intervention | Outcomes
Dula (2000) ^146^ Funding source: TAP Holdings Inc. | N screened = NR N randomized = 569 IG1, n = 242 IG2, n = 119 IG3, n = 89 CC, n = 119 ITT analysis used for primary outcome: NR Inclusion: age 21–73; in stable heterosexual relationship for ≥6 mo; failed to achieve and maintain firm erections for satisfactory intercourse in ≥50% of attempts in last 3 mo Exclusion: MS; SCI; Parkinson's disease; hypogonadism; hyperprolactinemia; uncontrolled diabetes or hypertension; radical prostatectomy; major penile deformity or penile prosthesis; ED tx in preceding 3 mo; hx of drug or alcohol abuse within past 2 yr; AIDS or positive HIV test; hx of cancer; allergy to opiates; partner breast-feeding, pregnant or with hx of major affective disorder (IG1 vs. IG2 vs. IG3 vs. CG) | Age, mean (range): 55 (21–72) vs. 55 (37–71) vs. 55 (26–73) vs. 56 (25–71) y Race,(range %): White 90–92%; African-American 1–7%; other 2–7% Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: % of pts with one or more of following hypertension 29%; diabetes 6%; benign prostatic hyperplasia 16%; CAD 12% Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: ED severity, (%): severe 35%; moderate 37%; mild 28% (determined by IIEF) | IG1/2/3: apomorphine -sublingually CG: placebo-sublingually IG1/2/3: Dose: IG1=2, 4, 5, 6 mg (dose optimizing grp); IG2= 5 mg; IG3=6 mg Duration: 8 wk ( 4 wk, dose adjustment + 4 wks steady dosefor IG1) Frequency: wk 1–4: 2–5 doses/wk; wk 5–8: ≥2 doses/wk Compliance: NR CG: Dose: placebo Duration: 8 wk Frequency: wk 1–4: 2–5 doses/wk; wk 5–8: ≥2 doses/wk Compliance: NR Run In period: None Wash out period: NA F/u duration: 8 wk | Primary outcome results: Erection firm enough for intercourse, (%): Baseline: 26 vs. 21 vs. 28 vs. 24 Post tx: 53 vs. 53 vs. 53 vs. 35 (▴ in %=27 vs. 32 vs. 25 vs. 11) Attempts resulting in erection firm enough for intercourse, (%): Baseline: 26 vs. 21 vs. 26 vs. 23 Post tx: 50 vs. 51 vs. 50 vs. 33 (▴ in %=24 vs. 34 v. 30 vs. 10) Other outcomes assessed: Partner rated erection; time to erection Withdrawals/drop-outs/loss to f/u: IG 111 (25), CG 14 (12) WDAE: 25 (10) vs. 8 (7) vs. 8 (9) vs. 1 (1) TAE: NR AE in 10% or more of pts, (%), [1^st^ 4 wks; 2^nd^ 4 wks]: nausea [25; 12] vs. [34; 12] vs. [44; 17] vs. [3; 0]; headaches [16; 6] vs. [12; 2] vs. [19; 6] vs. [10; 4] dizziness [11; 4] vs. [14; 4] vs. [16; 6] vs. [0; 0]; sweating [10; 5] vs. [10; 0] vs. 16; 1] vs. 1; 0]; yawning [10; 3] vs. [14; 0] vs. [16; 0] vs. [6; 0]; somnolence [7; 2] vs. 15; 4] vs. [11; 0]; [2; 1] Note: AE data reported for n=197 vs. n=94 vs. n=70 vs. n=105) SAE: 0 Ascertainment of outcomes assessed: IIEF; partners brief Sexual Functional Inventory
Dula (2001) ^147^ Study a Funding source: TAP Pharmaceuticals Inc. | N screened = NR N randomized = 194 (cross over) IG/CG, n = 194 ITT analysis used for primary outcome: No Inclusion: male with ED 3 mo or longer, in stable sexual relationship 6 mo or longer; controlled diabetes, hypertension, benign prostate hypertrophy, and CAD Exclusion: unable to achieve at least 55% base rigidity for 10 min on at least once/ two nights; sign neurological dx, endocrine, genito/urinary or psychiatric dx, HIV, AIDS, cancer in remission; drug abuse, hypersensitivity to morphine, recent tx for ED, use of metoclopramide Introduction of or dose changes in anxiolytics, serotonin reuptake inhibitors, beta-blockers, thiazide diuretics, alpha-methyl dopa, clonidine; penile fibrosis; severe pyronie's dx, or prior penile prosthesis | Age, mean (range): 56.7 (27–72) y Race n (%): Caucasian: 166 (86) African-American: 13 (7) Hispanic: 13 (7) Other: 2 (1) Co-morbidities, n (%): Hypertension: 85 (44) Diabetes: 30 (16) Benign prostatic hypotrophy: 49 (25) CAD: 19 (10) None: 79 (41) Previous ED treatment: NR Smoking status: NR Body weight mean, (range): 179 (155–198) kg | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: severity of ED, n (%)= severe 62 (32), moderate 56 (29), mild 52 (27), none 1 (0.5), not specified 23 (12) | IG: sublingual formulation of apomorphine CG: placebo formulation IG: Dose: 3 mg Duration: 4 wks Frequency: minimum twice /wk with at least 8 hr in between doses Compliance: 84% CG: Dose: NA Duration: 4 wks Frequency: as IG Compliance: 84% Run In period: 2–4 wks Wash out period: 24–96 hrs F/u duration: NR | Primary outcome results: Percentage attempts resulting in erection firm enough for intercourse IG1: 46.9% CG: 32.3% IG1 significantly superior to CG across all severities of ED Other outcomes assessed: Time to erection Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE, n (%): AE reported by 5% or more of pts= 61/185 (33) vs. 24/177 (14); including: nausea 13 (7) vs. 2 (1); yawning 15 (8) vs. 1 (0.6); dizziness 12 (7), vs. 6 (3); somnolence 9 (5) vs. 3 (2), headache 4 (2) vs. 8 (5); vasodilatation 4 (2) vs. 4 (2) SAE: 0 Ascertainment of outcomes assessed: RigiScan, home diaries, Brief Sexual Function Inventory, IIEF
Dula (2001) ^147^ Study b Funding source: TAP Pharmaceuticals Inc. | N screened = NR N randomized = 102 (cross over) IG1/IG2, n = 102 ITT analysis used for primary outcome: No Inclusion: male with ED 3 mo or longer, in stable sexual relationship 6 mo or longer; controlled diabetes, hypertension, benign prostate hypertrophy, and CAD Exclusion: unable to achieve at least 55% base rigidity for 10 min on at least once/ 2 nights; sign neurological dx, endocrine, genito/urinary or psychiatric dx, HIV, AIDS, cancer in remission; drug abuse, hypersensitivity to morphine, recent tx for ED, use of metoclopramide Introduction of or dose changes in anxiolytics, serotonin reuptake inhibitors, beta-blockers, thiazide diuretics, alpha-methyl dopa, clonidine; penile fibrosis; severe pyronie's dx, or prior penile prosthesis | Age, mean (range): 57 (32–71) y Race n (%): Caucasian: 87 (85) African-American: 9 (9) Hispanic: 5 (5) Other: 1 (1) Co-morbidities, n (%): hypertension: 35 (34) Diabetes: 12 (12) Benign prostatic hypertrophy: 20 (20) Coronary artery disease: 12 (12) None: 46 (45) Previous ED treatment: NR Smoking status: NR Body weight, mean (range): 178 (155 – 199) kg | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: severity of ED, n (%)= severe 32 (31); moderate 35 (34); mild 20 (20); not specified 15 (14) | IG1: apomorphine-sublingual IG2: apomorphine-sublingual IG1: Dose: 3 mg Duration: 4 wks Frequency: minimum twice /wk with at least 8 hr in between doses Compliance: 78% IG2: Dose: 4 mg Duration: 4wks Frequency: as IG1 Compliance: 78% Run In period: 2–4 wks Wash out period: 24–96 hrs F/u duration: NR | Primary outcome results: Percentage of attempts resulting in erection firm enough for intercourse 49% vs. 50% Other outcomes assessed: Proportion of attempts culminating in successful intercourse Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE, n (%): AE reported by 5% or more of pts= 23/90 (26) vs. 51/92 (55); included nausea 3 (3) vs. 13 (14); yawning 8 (9) vs. 12 (13); dizziness 2 (2) vs. 5 (5); somnolence 5 (6) vs. 9 (10); headache 4 (4) vs. 6 (7); vasodilatation 1 (1) vs. 6 (7) SAE: 0 Ascertainment of outcomes assessed: RigiScan, pts diaries, IIEF, Brief Sexual Function Inventory
Eardley (2004) ^148^ Funding source: NR | N screened = NR N randomized = 139 (cross over open label) IG1, n = 66 (sildenafil - apomorphine) IG2, n = 65 (apomorphine - sildenafil) CG randomized = NA ITT analysis used for primary outcome: Yes (n=118) Inclusion: male pts with ED (Sexual Health Inventory-Male score <= 21) aged > 18 yrs, in a stable relationship Exclusion: pts taking concomitant nitrates, hypersensitivity to morphine, previous treatment for ED, concurrent dosing with the inhibitor of the CYP3A4 enzyme system, unstable CVD, hx of retinitis pigmentosa, and other major hepatic renal or haematological abnormalities | Age, mean (range): 57.6 (39–77) vs. 54.7 (28–82) y Race: White 92%; other 8% Co-morbidities: NR Previous ED treatment: None Smoking status: NR Body weight, mean (sd): 86 (17) vs. 87 (16) kg Other: mean height= 177 vs. 175 cm | Concomitant medications: None Duration of ED, mean (range): 4.7 (0.2–25) vs.3.3 (0.2–17) y Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: sildenafil (1^st^ period)/apomorphine (2nd) IG2: apomorphine (1^st^)/sildenafil (2nd) IG1: Dose: NR Duration: 8 wks (given in 1st or 2nd period) Frequency: NR Compliance: n=5 pts did not take sildenafil IG2: Dose: NR Duration: 8 wks (given in 1st or 2nd period) Frequency: NR Compliance: n=8 pts did not take apomorphine Run In period: 2 wks Wash out period: 2 wks F/u duration: 8 wks for each drug; chronological = 18 wks (2 periods and wash out period combined) | Primary outcome results: Sildenafil vs. apomorphine, adjusted mean (95% CI): IIEF-EF score: Post tx: 25 (24–27) vs. 16 (14–17) Tx 9.3 (7.6–11) OS: Post tx: 8.5 (8–9) vs. 6 (5.4–6.3) Tx difference: 2.7 (2–3) EDITS ‘successful intercourse attempts (% of pts): Post tx: 75 (69, 81) vs. 35 (29–41) Tx difference: 40 (33, 46.5) EDTS, total score: Post tx: 82.5 (78–87) vs. 47 (42–52) Tx difference: 36 (30–41) Other outcomes assessed: OF, sexual desire; Withdrawals/drop-outs/loss to f/u: n = 21 WDAE, n (%): 5 (8); including n=2 (sildenafil), MI; postural hypotension, dizziness, & shortness of breath; n=3 (apomorphine), suspected MI; headache and blurred vision; nausea) TAE: 110 (in n=62) vs. 53 (in n=42) SAE: n=5, suspected MI, Dupuytren's contracture (apomorphine) vs. deterioration of an arthritic shoulder and MI, atrial fibrillation (sildenafil), one atrial fibrillation 30 d post end of tx Ascertainment of outcomes assessed: IIEF, EDITS
Gontero (2005) ^149^ Funding source: NR | N screened = 154 N randomized = 130 IG, n = 65 CG, n = 65 ITT analysis used for primary outcome: no Inclusion: diabetic men (type I and II) with hx of ED, lasting at least 3 mo. for which never received treatment Exclusion: any major psychiatric disorder, absence of stable partner, penile deformities, concomitant presence of a neurological disease (other than diabetes) | Age, mean (sd): IG 56.58(10.25), CG 56.05(9.65) Race (%): NR Co-morbidities: ischemic heart disease 17 vs. 21; nitrates 5 vs. 7; hypertension 44 vs. 38; cholesterol (> 200) 22 vs. 21 Blood glucose, mean (sd): 8 (2) vs. 8(1.7) HbA1C Previous ED treatment: NA Smoking status (%): 34% vs. 38 Body weight: NR Other: diabetes (%): type I= 15 vs. 15; type II (insulin)= 47 vs. 41 | Concomitant medications: NR Duration of ED, mean. (sd): 25 (26) vs. 23(19) mo Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: duration of diabetes, mean (sd): 12 (9) vs. 11 (8) y; Baseline IIEF-ER, mean (sd): responders=13 (6) vs. 13 (5); non-responders 13 (6) vs. 13 (6); pts with Erection grade 3 or higher, (%): responders 73 vs. 67; non-responders= 40 vs. 38 | IG: apomorphine SL, oral CG: placebo, oral IG: Dose: 3 mg Duration: 4 wks Frequency: X1, 15 min before sexual intercourse, max= once in 8-hr period Compliance (%): non-responders= 45%; responders= 10% did not take all tablets CG: Dose: 3 mg Duration: 4 wks Frequency: as IG Compliance (%): non-responders= 50%; responders= 12% did not take all tablets Run In period: NA Wash out period: NA F/u duration: NA | Primary outcome results: IIEF- EF domain: 13.8(6) vs. 13.2 (6) IIEF-Q3 (erection sufficient for intercourse): 2 (1) vs. 2 (1) IIEF-Q4 (ability to maintain erection): 2 (1) vs. 2 (1) = no sign. differences for all variables p > 0.05 IIEF-GEQ: affirmation responses 25 %, vs. 21% (P=0.65) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: 9% vs. 5% (nausea) SAE: 0 Ascertainment of outcomes assessed: IIEF-questionnaire; GEQ, 1 item (yes or no), IIEF-EF domain was considered sign. if improved by 5 point
Hagemann (2003) ^150^ Funding source: NR | N screened = NR N randomized = 12 IG, n = 6 CG, n = 6 ITT analysis used for primary outcome: NR Inclusion: Men with ED based on documentation of less than 50% successful attempts to attain and/or maintain an erection firm enough for intercourse with partner for a min of 90 d prior to study or if no attempts were made Exclusion: Men without ED | Age, mean (range): 35 (24–41) y Race: NR Co-morbidities: NR Previous ED treatment: NR Smoking status, n (%): 6 (50) Body weight, mean (range): 82 (65–93) kg, Other: consumed alcohol, n (%)= 9 (75) | Concomitant medications: None Duration of ED: Min 90 d prior to study Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: Apomorphine SL CG: Placebo IG: Dose: 4 mg Duration: 70 min Frequency: during Positron emission tomography (PET) procedures Compliance: 100% CG: Dose: placebo Duration: 70 min Frequency: as IG Compliance: 100% Run In period: None Wash out period: None F/u duration: NR | Primary outcome results: IG vs. CG n (%) RigiScan positive response 4 (67) vs. 0 (0) Other outcomes assessed: PET scan: ▴ cerebral activity post administration of apomorphine, associated with penile rigidity. Withdrawals/drop-outs/loss to f/u: None WDAE: None TAE, n (%): 0 vs. 2 (33) headache SAE: None Ascertainment of outcomes assessed: RigiScan monitoring penile rigidity during all PET procedures. (40%=positive response, below 40%=non-responsive) PET scan, 4 were performed in each pts following a 30 s video
Lammers (2002) ^151^ Funding source: NR | N screened = 68 N randomized = 43 (4 way cross over) IG1-4, n = 43 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: ED of ≥ 6mo, moderate to severe, in a stable monogamous heterosexual relationship, provided informed consent, informed partners of study participation Exclusion: ED caused by untreated endocrine dx, postural hypotension or uncontrolled hypotension, sign. penile pathology, hx of sign. hepatic or renal dx, CAD, nervous system dx, radical prostatectomy, uncontrolled psychiatric condition, known intolerance to study medications, concomitant use of organic nitrates, regular use of sympathetic-CNS depressors, blood donations (pts with ▾of >30% SBP, or DBP or ▴ of >30% HR after in office drug administration were withdrawn) | Age, range: 40–75 y Race: NR Co-morbidities: NR Previous ED treatment: many had used sildenafil, (and other study medications) Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (mo): ≥ 6 mo Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: phentolamine + apomorphine IG2: phentolamin + papaverine IG3: phentolamine + papaverine + apomorphine IG4: sildenafil IG1: Dose: 40 mg + 6 mg Duration: NA Frequency: once (in office) IG2: Dose: 40 mg +150 mg Duration: NA Frequency: as IG1 IG3: 40 mg+150 mg +6 mg Duration: NA Frequency: as IG1 IG4: Dose: 100 mg (not blinded) Duration: NA Frequency: as IG1 Compliance (all): 100% Run In period: 4 wks placebo Wash out period: NA F/u duration: 60 min post tx | Primary outcome results: SEP, mean ▴ from baseline: 1.9 vs. 1.6 vs. 1.7 vs. 1.8 Successful vaginal penetrations, mean proportion: Baseline: 0.13 Post tx: 0.5 vs. 0.4 vs. 0.5 vs. 0.4 GAQ (1–5), mean score: 2.9 vs. 2.9 vs. 2.9 vs. 2.5 Rigidity by VAS (baseline = 17): 45 vs. 44 vs. 45 vs. 46 Other outcomes assessed: Tx preference, duration and satisfaction; vaginal intercourse leading to orgasm Withdrawals/drop-outs/loss to f/u: 1 WDAE: 0 TAE: 150 (in 19 pts) including CV events 2 (5) in IG3, and 2 (5%) in IG4 Most frequent AEs: rhinitis 4 (10) vs. 2 (5) vs. 6 (15) vs. 3 (8); headache 2 (5) vs. 1 (2) vs. 1(2) vs. 3 (8); dyspepsia 2 (5) only in IG3; nausea 2 (5) only in IG2 SAE: 1 hospitalization for right nephrectomy, (grp NR) Ascertainment of outcomes assessed: SEP; visual analogue scale of 0–100 (VAS), GAE, reports of AE
Perimenis (2004) ^152^ Funding source: NR | N screened = NR N randomized = 40 IG1, n = 20 (apomorphine-sildenafil) IG2, n = 20 (sildenafil-apomorphine) CG, n = NA ITT analysis used for primary outcome? NR Inclusion: male outpatients with non-arteriogenic ED (repeated PSV 25 cm/s or higher), with a stable relationship of 6 mo or longer, age 18–80 yrs Exclusion: penile or testicular deformity, SCI, severe neurological dx, hormonal deficiency, severe BP abnormality or hx of retinitis pigmentosa, tx with vacuum devices, IC injections, testosterone or nitrates | Age, mean: 56. y, 95% CI= 53.9, 57.6 Race: NR Co-morbidities, (%): DM (17.5), hypertension (50), Ischemic cardiac disease (12.5), dyslipidaemia (37.5) Previous ED treatment: NR Smoking status: smokers (95%) Body weight: NR Other: mean IIEF-5 score = 17, 95%CI: 16.1, 18.4; mean PSV: 31.5 cm/s, 95% CI: 28.8, 33.1 | Concomitant medications: pts were receiving medications to control comorbidities during trial (not specified) Duration of ED, mean: 9.2 mo, 95%CI: 7.1, 11.3 Underlying disease: NR Psychogenic ED: NR Physiologic ED: non-arteriogenic 100% Mixed ED: NR | IG1: apomorphine IG2: sildenafil IG1: apomorphine Dose: 2–3 mg Duration: 6 wks (given in 1st or 2nd period) Frequency: once/d Compliance: NR IG2: sildenafil Dose:50–100 mg Duration: 6 wks (given in 1st or 2nd period) Frequency: once/d Compliance: NR Run In period: NR Wash out period: 1 wk F/u duration: 6 wks for each drug; chronological = 13 wks (1,^st^ 2^nd^ periods, and wash out period combined) Other: for apomorphine and sildenafil the dose was titrated 2–3 mg and 50–100 mg respectively if the patient was not satisfied with the effectiveness | Primary outcome results: of successful intercourse attempts, n/N (%) = IG1: 326/520 (63%) IG2: 373/510 (73%), p < 0.0004 (two periods combined) Other outcomes assessed: tx satisfaction Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: Questionnaires Other: the pts' response to 2 mg apomorphine & 50 mg sildenafil was age-related (p < 0.05), but not related to ED duration, PSV, or IIEF score
Perimenis (2004) ^153^ Funding source: NR | N screened = NR N randomized = 43 IG1 randomized = 24 (apomorphine 1^st^ period; sildenafil 2^nd^) IG2 randomized = 19 (sildenafil 1^st^, apomorphine 2^nd^) CG randomized = NA ITT analysis used for primary outcome: NR Inclusion: male outpatients with ED with a stable relationship of 6 mo or longer, repeated PSV lower than 25 cm/s Exclusion: penile or testicular deformity, SCI, hormonal deficiency, severe blood pressure abnormality or hx of retinitis pigmentosa, tx with vacuum devices, IC injections, T or nitrates tx | Age, mean (sd): 59.2, 95%CI: 57.3, 61.2 Race (%): NR Co-morbidities, (%): DM (17), hypertension (47), CVD (9), respiratory obstruction (5), transurethral prostatectomy (5), depression (2), heart failure (2) Previous ED treatment: NR Smoking status: smokers (95%) Body weight: NR Other: mean IIEF-5 score = 7.9, 95%CI: 7.07–8.74; mean penile PSV: 20.7 cm/s, 95%CI: 19.5, 21.9 | Concomitant medications: pts were receiving medications to control co-morbidities during trial Duration of ED, mean: 19.3 mo, 95%CI: 13.1, 25.4 Underlying disease: NR Psychogenic ED: NR Physiologic ED: arteriogenic 100% Mixed ED: NR | IG1: apomorphine IG2: sildenafil IG1: Dose: 2–3 mg Duration: 6 wks (given in 1st or 2nd period) Frequency: once/d Compliance: NR IG2: Dose:50–100 mg Duration: 6 wks (given in 1st or 2nd period) Frequency: once/d Compliance: NR Run In period: NR Wash out period: 1 wk F/u duration: chronological = 13 wks (1,^st^ 2^nd^ periods, and wash out period combined) Other: for apomorphine and sildenafil the dose was titrated 2–3 mg and 50–100 mg respectively if not satisfied | Primary outcome results: Apomorphine vs. sildenafil of successful intercourse attempts, n/N (%) 1^st^ + 2^nd^ period= 189/588 (32%) vs. 375/589 (64%), p < 0.01 1^st^ period= 31.3% vs. 62.6% 2^nd^ period= 32.9% vs. 64.8% n/N (%) of successful intercourse attempts= Other outcomes assessed: satisfaction with tx Withdrawals/drop-outs/loss to f/u: n=2 (apomorphine) WDAE: n=2 (apomorphine) due to repeated nausea, syncope episode (in a pt who consumed alcohol) TAE: apomorphine: 6 (14%) including nausea, headache, dizziness and syncope vs. sildenafil: 3 (7%) including headache, dyspepsia SAE: NR Ascertainment of outcomes assessed: Questionnaires (event log)
Porst (2007) ^154^ Funding source: NR | N screened = NR N randomized = 131 (cross over) IG1, IG2 n = 131 (1:1 to either arms: IG1sildenafil then apomorphine n=68 vs. IG2 apomorphine then sildenafil, n=63) CG: NA ITT analysis used for primary outcome: yes (n=116) Inclusion: men with ED, IIEF-5 of 21 or lower, in stable relationship Exclusion: hypersensitivity or any components of study medication or to opiates, major genital deformities leading to difficulties in performing intercourse, serious CV conditions, ED tx known to induce side effects, alcohol or drug abuse within last 30 d also excluded | Age, mean (sd): 53 (12) y, range 22–77 y Race: White 98% Black 1%; other 1% Co-morbidities, n (%): hypertension 27.9%; DM 9.3%; dyslipidemia 7%; CAD 4.6%; Previous ED treatment: NR Smoking status: NR Body weight: 85 (11.7) kg | Concomitant medications, n (%): NR Duration of ED, mean (range): 4.2 (0.2–30.6) vs. 3.5 (0.1–13.8) y Underlying disease, n (%): NR Psychogenic ED, n (%): 18 (26.5) vs. 23 (37.7) Physiologic ED, n (%): 19 (27.9) vs. 17 (27.9) Mixed ED, n (%): 31 (45.6) vs. 21 (34.4) | IG1: Sildenafil IG2: Apomorphine IG1: Dose: initial 50 mg (adjusted to 25–100 based on efficacy and tolerability after 4 wks; 55% titrated up and 5% titrated down) Duration: 8 wks Frequency: on demand Compliance: see dropouts IG2: Dose: initial 2 mg (adjusted to 2–3 afer 4 wks; 88% of pts titrated up) Duration: 8 wks Frequency: as IG Compliance: as IG Run In period: 2 wks Wash out period: 2 wks F/u duration: f/u measures at end of each 8 wks tx period | Primary outcome results: IIEF, mean sum score: EF: 23.6 vs. 12.8, P<0.0001 IS: 12 vs. 9.2, P<0.0001 OS: 8.2 vs. 5.7, P<0.0001 Individual IIEF questions mean difference from baseline (sd): Q2: 1.9 (1.5) vs. 0.6 (1.3) Q3: 1.8 (1.5) vs. 0.7 (1.2) Q4: 1.8 (1.6) vs. 0.6 (1.2) Successful intercourse attempts: 62.7% vs. 28.3% GEQ, % improved: 88.7% vs. 43.1% Other outcomes assessed: adjusted mean tx difference between grps Withdrawals/drop-outs/loss to f/u, n (%): 11 (8.4) did not complete the study; 15 (11) excluded from analysis; 8 completed one phase WDAE, n (%): 1 (0.8) TAE, n: 65 vs. 35; pts with AE= 45 (35.7) vs. 27 (21.8) most common were headache, flushing, dyspepsia and rhinitis vs. headache and nausea SAE, n (%): 2 (1.6) vs. 1 (0.8); including 1 death Ascertainment of outcomes assessed: IIEF, EDITS and GEQ, Q1 and Q2
von Keitz (2002) ^155^ Funding source: NR | N screened = NR N randomized = 507 IG1, n = 254 CG, n = 253 ITT analysis used for primary outcome: Y Inclusion: heterosexual; in stable health; aged 18–70; hx of ED; some intrinsic penile function; in stable sexual relationship for ≥6 mo Exclusion: MS, or SCI; hypogonadism; serum T < 8.3 nmol/L; uncontrolled diabetes; HbA_1C_ >10%; episode of ketoacidosis in last 3 mo; radical prostatectomy; penile prosthesis; penile deformity; pelvic surgery; uncontrolled hyper or hypotension; MI within last 6 mo; unstable angina; any major CV impairment; hx of drug of alcohol abuse; positive HIV or hepatitis B surface antigen; cancer with dx-free interval <5 yr; ED medication within last 2 wk prior to randomization; hx of allergic reaction to opiates | Age, mean (range): 55 (22–70) y Race (%): white 99 Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, (%): used at least one medication, 63 vs. 51 Duration of ED: NR Underlying disease, (%): Hypertension 24 vs. 19 CAD 1 vs. 10 Diabetes 10 vs. 8 Benign prostatic hyperplasia 5.5 vs. 6 Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: apomorphine SL- sublingually CG: placebo sublingually IG: Dose: 2 mg initially, ▴ by 1 mg at 2 and 4 wk (forced dose escalation regimen) Duration: 8 wk Frequency: once/ 8 hrs 1/8 hrs Compliance: NR CG: Dose: placebo Duration: 8 wk Frequency: as IG Compliance: NR Run In period: None Wash out period: NA F/u duration: 8 wk | Primary outcome results: Erections sufficient for intercourse (%): 62 vs. 55 (p=0.021) Successful attempts resulting in sexual intercourse (%): Overall: 38 vs. 28 3 mg apomorphine vs. CG: 35 vs. 26 Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u, n (%): 33 (13) vs. 33 (13) WDAE, n (%): 12 (5) vs. 4 (2) TAE: 400 (in n=158) vs. 131 (in n= 62) SAE: 9 in n=6; 3 events considered related to study drug: IG1: syncope and vomiting in n=1 CG: angina pectoris of moderate intensity in n=1 Ascertainment of outcomes assessed: diary card

List of abbreviations: %=percent, ▴=increased, ▾=decreased, AE=adverse event, SAE=serious adverse event, BMI=body mass index, CC=controlled clinical trials, CG=comparator/control group, ctrls=controls, DM=diabetes mellitus, E_1_ IC=intracavernosal injection, ECG=electrocardiograms, ED=erectile dysfunction, EDV=end-diastolic velocity, f/u=follow-up, FMD=flow mediated dilation, GAQ=global assessment question, GEQ=global efficacy question, grp=group/s, HbA1C=haemoglobin, hr=hour(s), hx=history, IG=intervention group, IIEF= international index of erectile function (EF=erectile function, OF=orgasmic function, OS=overall satisfaction, SD=sexual desire), ITT=intent-to-treat (Y=yes, N=no, NR=not reported), IU=intraurethral, kg=kilograms, lbs=pounds, LUTS=lower urinary tract symptoms, M=male, max=maximum, mo=month(s), NA=not applicable, PADAM=partial androgen deficiency of the aging male, PgE_1_=Prostagladin, PRL=prolactin, PSA=prostate-specific antigen, RAU=rigidity activity unit, RCT=randomized control trial, SBP=systolic blood pressure, sign.=significant; TAE=total adverse events, TAU=tumescence activity unit, vs.=versus, WDAE=withdrawals resulting from adverse events, wk=week(s), yr=year(s).

Evidence Table C5. Intracavernousal Injection Trials

Author Funding | N; study design; eligibility | Participants characteristics | Diagnosis details | Intervention | Outcomes
Allen (1992) ^156^ Funding source: NR | N screened = NR N randomized = 7 Cross over design IG1/IG2/IG3, n = 7 CC, n = NA ITT analysis used for primary outcome: NR Inclusion: men with organic ED, abnormal nocturnal penile tumescence Exclusion: NR | Age, mean (sd): NR Co-morbidities: NR Previous ED treatment: Effective Papaverine + phentolamine IC ≥1 mo before Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: 0 Physiologic ED: 7 (100%) Mixed ED: 0 | IG1: Papaverine + Phentolamine IG2: Papaverine + Phentolamine + PgE_1_ IG3: Papaverine + PgE_1_ IG1: Dose: Papaverine 30 mg/ml + phentolamine 5 mg/ml IG2: Dose: a + PgE_1_ 5 μg/ml IG3: Dose: Papaverine 30 mg/ml + PgE_1_ 5 μg/ml Frequency: two injections/d (a+ either b or c) Compliance, all: 86% Run In period: NR Wash out period: time to de-tumescence to be (<5 mm from baseline) at each test d; 1 wk between two test d, NR F/u duration: NA tumescene between injections | Primary outcome results: Duration: mean valued longer than a in IG3 (p=0.002), and trimix (p=0.001) Mean max rigidity: both combination of PgE1 better than (no sign) Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: 1 drop-out, post single intervention of 2 injections WDAE: NR TAE: NR (no pain observed) SAE: NR Ascertainment of outcomes assessed: RigiScan for penile rigidity Erection duration timed: started when > 80% of max and stopped < 80% for ≥ 20 min
Aversa (1996) ^157^ A: (single-blind trial) Funding source: NR | N screened = NR N randomized = 24 (cross over) IG1/IG2, n = 24 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: pts 20–45 yrs with non-organic ED => 6 mo duration (inability t achieve or maintain adequate erection for successful coitus), normal testicular size, no concomitant disease, no recent hx of drug abuse, normal cella turcica roentgenograms, normal results of neurological, vascular and clinical chemistry (3h glucose tolerance, liver and renal function tests), and normal basal serum levels (PRL < 25 ng/ml, testosterone> 653 nmol/l) Exclusion: NR | Age, range: NR (20–45) yrs (based on total sample from 2 separate trials (study a and b) Co-morbidities: NR Previous ED treatment: NR Smoking status: n=18 (total in 2 separate trials Body weight: NR | Concomitant medications: NR Duration of ED (yr): => 6 mo Underlying disease: NR Psychogenic ED: 100% Physiologic ED: None Mixed ED: NR | IG1: PgE1 IG2: PgE1 + phentolamine IG1: Dose: 20 μg/ml Duration: NA Frequency: once Compliance: NR IG2: Dose: 20 μg/ml (PgE1) 0.5 μg/ml (phentolamine) Duration: NA Frequency: once Compliance: NR Run In period: 12 hr (no smoke, no coffee) Wash out period: 7 d F/u duration: 7 d (assessments done 15 min after the injections) | Primary outcome results: N (%) pts with full response (IG1 vs. IG2) = 5 (21%) vs. 13 (54%), p < 0.05 N (%) pts with partial response (IG1 vs. IG2) = 10 (42%) vs. 8 (33%), p = NR % pts with a valid-for-intromission erection (IG1 vs. IG2) = 63% vs. 87%, p < 0.05 Mean duration of erection (IG1 vs. IG2) = 112 (7.9) vs. 130 (8.5), p = NR Other outcomes assessed: level of anxiety Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE: mild to moderate discomfort in 21%; prolonged erection in 2: 1 IG1 (4%); 1 in IG2 (4%) Note: % of pts reported for combined data, n=34 SAE: NR Ascertainment of outcomes assessed: questionnaires; axial rigidity by tonometer, and radial rigidity by RigiScan
Aversa (1996) ^157^ B:(single-blind trial) Funding source: NR | N screened = NR N randomized = 10 (cross over) IG1/ IG2, n= 10 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: pts 20–45 y with non-organic ED => 6 mo duration (inability t achieve or maintain adequate erection for successful coitus), normal testicular size, no concomitant disease, no recent hx of drug abuse, normal cella turcica roentgenograms, normal results of neurological, vascular and clinical chemistry (3h glucose tolerance, liver and renal function tests), and normal basal serum levels (PRL < 25 ng/ml, testosterone> 653 nmol/l) Exclusion: NR | Age, range: (20–45) y (based on total sample from 2 separate trials Co-morbidities: NR Previous ED treatment: NR Smoking status: n=18 (total in 2 separate trials Body weight: NR | Concomitant medications: NR Duration of ED (yr): => 6 mo Underlying disease (diagnosis) (N or % of diseased/ grp): NR Psychogenic ED: 100% Physiologic ED: None Mixed ED: NR | IG1: PgE1 IG2: PgE1 + phentolamine IG1: Dose: 25 μg/ml Duration: 7 d Frequency: NR Compliance: NR IG2: Dose: 25 μg/ml (PgE1) 0.5 μg/ml (phentolamine) Duration: 7 d Frequency: NR Compliance: NR Run In period: NR Wash out period: NR F/u duration: 7 d (assessments done 15 min after the injections) | Primary outcome results: N (%) pts with full response (IG1 vs. IG2) = 3 (30%) vs. 6 (60%), p < 0.05 N (%) pts with partial response (IG1 vs. IG2) = 3 (30%) vs. 3 (30%), p = NR % pts with a valid-for-intromission erection (IG1 vs. IG2) = 60% vs. 90%, p < 0.05 Mean duration of erection (IG1 vs. IG2) = 115 (8.5) vs. 135 (10.5), p = NR Other outcomes assessed: level of anxiety Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: questionnaires
Baum (2000) ^158^ Funding source: Upjohn Pharmaceutical Company | N screened = 50 N randomized = 50 (parallel) IG, n= 25 CG, n= 25 ITT analysis used for primary outcome: No Inclusion: psychogenic ED, assessed by preservation of full, rigid morning or nocturnal erection and rigid erection with self-stimulation or masturbation Exclusion: endocrin cause of ED Data reported for IG vs. CG | Age, mean: 49.6 vs. 50.1 Race (%): 64% White; 32% Black; 2% Hispanic; 2% Oriental Co-morbidities: NR Previous ED treatment (n): IG1 vs. CG None 22 vs. 24 Oral medications 2 vs. 1 Vacuum or other device 1 vs. 0 Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean: 3.5 vs. 4.4 y Underlying disease: NR Psychogenic ED: 50 (100%) Physiologic ED: NR Mixed ED: NR | IG: Low dose PgE1 + information + instructional video CG: standard sex therapy IG: Dose: 2.5–5.0 μg (initial 2.5 μg + 2.5 μg after 60 min if erection <75% of pts normal erection, Optimum dose:produced erection lasting 60 min or more with rigidity adequate for intercourse) Duration: 12 wks Frequency: up to 3×/wk with at least 24 hr between doses Compliance: 52 % CG: Dose: up to 12 Duration: NR Frequency: 1×/wk Compliance: 64 Run In period: NR Wash out period: NR F/u duration: assessment at wks 4,8,12 | Primary outcome results: IG vs. CG Improvement in obtain un-aid erection: 47% vs. 58% Duration of erection: 35 vs. 10 min sex situations producing erection: 63% vs. 82% Extremely satisfied with treatment: 69% vs. 75% Improvement in Sexual Life Quality Questionnaire Subscale: 74 vs. 71 points Frequency of intercourse: 20.5 vs. 20 Other outcomes assessed: Prediction of ability to perform 6 mo in future, cost comparison of treatment arms Withdrawals/drop-outs/loss to f/u: 12 (48%) vs. 9 (36%) WDAE: 0 TAE: penile bleeding & pain, n=1 in IG, n=1 report of ecchymosis also in IG SAE: NR Ascertainment of outcomes assessed: Sexuel Life Quality Questionnaire (SLQQ), RigiScan device
Bechara (1996) ^159^ Funding source: NR | N screened = NR N randomized = 32 (crossover design) IG1/IG2, n= 32 CG randomized = NA ITT analysis used for primary outcome: NR Inclusion: lack of response to 2 consecutive tests with papaverine plus phentolamine Exclusion: NR | Age, mean (range): 61 (26–71) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): 2.56, range 0.5–4.25 Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: PgE_1_ + visual and manual stimulation IG2: Trimix + visual and manual sexual stimulation CG: NA IG1: Dose: 40 μg Duration: NR Frequency: 1 dose Compliance: NR IG2: Dose: 17.64 mg papaverine, 0.58 mg phentolamine, 5.8 μg PgE_1_ Duration: NR Frequency: 1 dose Compliance: NR Run In period: NR Wash out period: ≥ 1 wk F/u duration: NR | Primary outcome results: examiner assessment of response on 5-point scale from E0 (no tumescence) to E5 (full rigidity) 15 min after injection Grade 4 or 5 erection IG1: 7 (22%) IG2: 16 (50%) Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: 15 WDAE: NR TAE: NR (Pain 41% vs. 12.5%) SAE: NR Ascertainment of outcomes assessed: NR Other: NA
Bechara (1997) ^160^ Funding source: drugs by Farmacica | N screened = NR N randomized = 60 (cross over design) IG/CG = 60 (randomized into 6 grps, details of these grps NR) ITT analysis used for primary outcome: NR Inclusion: pts with hx of ED longer than 6 mo Exclusion: major neurological impairment secondary to SCI or radical pelvic surgery; previous use of self injected vasoactive drugs, or previous pharmacological erection test | Age, mean (range): 58 (22–6–78) y Co-morbidities: NR Previous ED treatment: NA Smoking status: NR Body Weight NR | Concomitant medications: NR Duration of ED: More than 6 mo Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: Papaverine + phentolamine; IG2: PgE1 CG: placebo IG1: Dose: 30 mg/ml papaverine + 0.5 mg/ml phentolamine (1 ml solution) Duration: NA Frequency: once/ wkl Compliance: 100% IG2: Dose: 30 μg/ml prostaglandine (1 ml solution) Duration: NA Frequency: once/ wkl Compliance: 100% CG: Dose: placebo: 1 ml isotonic sodium chloride solution Duration: NA Frequency: once/ wkl Compliance: 100% Run In period: NR Wash out period: 1 wk F/u duration: NR Other: Data provided for 3 intervetion type | Primary outcome results: Erection response (IG1 vs. IG2 vs. CG) [N erectile response (%)]: Grade 4: 20 (33) vs. 16 (27) vs. 0 Grade 5: 14 (23) vs. 14 (23) vs. 0 Grade 4+5: 34 (56) vs.30 (50) vs. 0 Other outcomes assessed: Systemic effects: No effects were noted Withdrawals/drop-outs/loss to f/u: n=0 WDAE: n=0 TAE: Total pts with AE: NR Prolonged erection lasting more than 3 hr, n (%): 11 (18) vs. 9 (15) vs. 0 Pain: 9 (15) vs. 21 (35) vs. 0 SAE: NR Ascertainment of outcomes assessed: Manual & visual sexual stimulation at 10, 20 and 30 min post injection- erectile responses classified as E0 = no tumefaction to E5=full rigidity (E4–5= positive, E0–3 = negative)
Buvat (1998) ^161^ Funding source: Schwarz Pharma A.G., Mannheim, Germany | N screened = 186 N randomized = 156 IG1, n= 81 IG2, n= 75 CG, n= NA ITT analysis used for primary outcome: NR Inclusion: Age 18–70 y; with ED of 6 mo or longer in duration Exclusion: Drug/alcohol addiction; presence of other severe disease (e.g. unstable angina, MI) within 3 mo before study start; urological pathology responsible for ED (e.g. hypospadias); ED of hormonal origin; concomitant treatment with other vasoactive agents; hx of Peyronie's disease' anatomical deformation of penis | Age, mean (sd): 53.7 (10.8) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean (sd): 4.5 (5.2) y Underlying disease: NR Psychogenic ED, n (%): 73 (46%) Physiologic ED: 41 (26%) Mixed ED, n (%): 43 (28%) Other: NA | IG1: moxisylyte chlorhydrate IG2: PgE1 (alprostadil α-cyclodextrin) IG1: Dose: 10–20 mg Duration: 6 wk Frequency: up to 6 injections/ 6 wks Compliance: NR IG2: Dose: 10–20 μg Duration: 6 wk Frequency: up to 6 injections/ 6 wks Compliance: NR Run In period: NR Wash out period: NR F/u duration: 6 wk | Primary outcome results: IG 1 vs. IG2 Penile buckling test with axial loading force of 1 kg, (clinic): ≥ 1 positive test: 32 (40%) vs. 56 (75%) Occurrence of rigid erection after self-injection, (home): ≥1 positive test: 37/61 (61%) vs. 58/68 (85%) Other outcomes assessed: positive buckling test by subgroups of psychogenic s. physiologic vs. mixed Successful injections; patient & partner opinion of tx Withdrawals/drop-outs/loss to f/u: NR WDAE NR TAE: IG1 vs. IG2, (%): Pain during injection: clinic 15 vs. 15; home 13 vs. 25 Pain during erection: clinic 3 vs. 35; home 17 vs. 24 Pain after erection: clinic 0 vs. 5; home 7 vs. 19 Bleeding: clinic 3 vs. 5; home 3 vs. 15 Erection > 2 hr: clinic 0 vs. 2; home 5 vs. 4 Dizziness/hypotension: home 8 vs.1 SAE: 0 Ascertainment of outcomes assessed: NA
Colli (1996) ^162^ Funding source: | N screened = NR N randomized = 45 (cross over) IG1-3/ CG, n= 45 ITT analysis used for primary outcome? No Inclusion: Men aged 18–65 yrs with ED of probable vascular, neurological and/or psychological origin of => 6 mo duration Exclusion: penile anatomical deformation, priapism or corporeal fibrosis, endocrine ED (serum testosterone < 120 ng/dl and PRL > 20 ng/ml), sickle cell anemia, hematologic diseases, systematic or psychiatric dx of recent onset, uncontrolled DM (fasting blood sugar > 300 mg/dl), uncontrolled hypertension (systolic > 150 and diastolic > 100 mmHg), hypotension (systolic < 100 mmHg), smokers (> 40 cigarettes/d), present use of PgE1 | Age, mean (sd): NR (NR); 20% (< 40 yrs), 33.3% (40–49 yrs), 37.7% (50–59 yrs), 8.8% (=> 60 yrs) Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): <= 1 yr (22.2%) 1–2 yrs (31.1%) 2–5 yrs (22.2%) 5–10 yrs (20%) > 10 yrs (4.4%) Underlying disease (diagnosis) (N or % of diseased/ grp): diabetes 2 (4.4%) Psychogenic ED: 24 (53.3%) Physiologic ED: vascular 12 (26.6%), neurologic 2 (4.4%) Mixed ED: Mixed 5 (11.1%) | IG1-3: PgE1 (alprostadil) CG: placebo IG1: PgE1 Dose: 5 μg (IG1), 10 μg (IG2), 20 μg (IG3) Duration: NA Frequency: one/wk Compliance (%): NR CG: placebo Dose: NR Duration: NA Frequency: one/wk Compliance (%): NR Run In period: NR Wash out period: 1 wk F/u duration: NR (assessments done 5–120 min after injection) | Primary outcome results: IG1 vs. IG2 vs. IG3 vs. CG ‘Full’ erection as assessed by clinical manual palpation (n): 12 vs. 23 vs. 4 vs. 0, p < 0.001 (likelihood ratio test for the treatment effect) ‘No’ erection as assessed by clinical manual palpation (n): 11 vs. 5 vs. 2 vs. 41, p < 0.001 (likelihood ratio test for the treatment effect) ‘Excellent’ erection- pts assessment (n): 5 vs. 9 vs. NR, vs. 0, p < 0.001 (likelihood ratio test for the treatment effect) ‘Full’ erection (70% or more rigidity at tip or base for 10 min), n: 17 vs. 25 vs. 7 vs. 0, p < 0.001 (likelihood ratio test for rigidity) Other outcomes assessed: latency of erection Withdrawals/drop-outs/loss to f/u NR WDAE: NR TAE: NR; AE reported as treatment-related n=3 (IG2) vs. n=1 (IG1) SAE: NR Ascertainment of outcomes assessed: manual palpation; RigiScan, questionnaires
Costa (1993) ^163^ Funding source: NR | N screened = NR N randomized =64 (cross over design: this grp received 3 single dose of active intervention a, b, c, & placebo IG1/2/3/CG, n = 64 Inclusion: Diagnosis of ED ITT analysis used for primary outcome? No Exclusion: Peyronie's disease; endocrine impotence; cardiac; renal; hepatic; ventilatory failure; systolic BP < 100 mm/Hg; neoplasm *Note: only values of IG3 is reported for outcome, since very similar to all other doses | Age, mean (range): 30 (20–50) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: IG2=32 Physiologic ED: Neurogenic 12 (34%) Mixed ED: NR Other: neither psychogenic or hormonal in 50% | IG1-3: Moxisylyte in 3 dosages, tourniquet at penis base CG: Placebo (Lyophilized Mannitol) IC (tourniquet used) IG1/IG2/IG3: Dose: 10, 20 and 30 mg (2 ml volume) Duration: NA Frequency: single CG: Dose: 2 ml placebo Duration: NA Frequency: single Compliance all: 95% (n=61) Run In period: 1 mo Wash out period: 7–15 d F/u duration: 2 wks post last IC | Primary outcome results: IG3* vs. CG (Max at 15 min for all parameters) Penile length/ circumference, mean (SE): At 0 min: 113 (3) vs. 113 (3) mm/ 93 (2) vs. 91(2) mm At 30 min post tx: 135 (3) vs. 133 (3) mm/ 110 (3) vs. 98 (3) mm Erection sufficient for intercourse, n (%): 53 (87) vs. 17 (28) Duration of erection, mean (range): 2 hrs (50 min – 4 hr) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: N=3 WDAE: NR TAE, n (%): mild pain during injection 4(5); hypotension + nausea 1 (1.4); prolonged erection (24h) 1 (1.4); faintness + normal BP 2 (2.8); drowsiness with all dose 1(1.4); sharp pain at injection1 (1.4); Hot flushes 1 (1.4); Rhinorrhea 4 (5) SAE: 1 sustained erection (24h) 10cc aspirated at 6hr to avoid priapism Ascertainment of outcomes assessed: Patient & clinician evaluated erection rigidity/ parameters
Dinsmore (1999) ^164^ Funding source: Senetek plc | IG screened = 236 IG randomized = 171 (parallel) IG1/ CG, n= 107 (ITT) IG2/ CG, n = 29 (ITT) ITT analysis used for primary outcome: Yes (per protocol analysis also reported) Inclusion: en 18 y or older, with ED of 1 y or longer in duration in stable heterosexual relationship Exclusion: overt psychogenic aetiology, ability to perform intercourse without medication or physical aid, hypoactive sexual dx, nocturnal or early morning erections, systemic dx, sickle-cell trait or dx; surgery, hormonal imbalance requiring treatment (except diabetes mellitus), angina pectoris, uncompensated congestive heart failure, hx of drug abuse (other exclusion lists could be found in the article) Note: Dose assessment phase: vasoactive intestinal polypeptide given by auto injector IC | Age, mean (range): 56.5 (25–81) y Co-morbidities: NR Previous ED treatment (n): IC PgE-1 n=96; papaverine/PM n=64; Other (yohimbine, vacuum devices) n=19 Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): NR Underlying disease: NR Psychogenic ED: NR Physiologic ED (%): 61% (arteriogenic 16%; DM 16%; neurogenic 16%; venous leakage 13%) Other 2% Mixed ED: 37% | IG: vasoactive intestinal polypeptide (VIP) + phentolamine meyslate (PM) IG1/IG2: Dose: 25 μg VIP, + 1mg (G1) or 2 mg (G2) phentolamine (dose of MP was established for each pts in the initial non-randomized dose assessment phase) in .35 mL volume Duration: 6 o Frequency: 10 injections in 6mo Compliance (96.5%) (n/grp): 136/141 CG: Dose: 35 mL solution Duration: as IG Frequency: two injections in 6 mo Compliance: as IG Run In period: NR Wash out period: at least 36hrs between injections F/u duration (both on and off treatment): NR | Primary outcome results: Erection suitable for intercourse (% of injections): IG1 75% vs. CG 12% IG2 66% vs. CG 18% Duration of erection, median in all grps: 56 min (range from 26 min in pts with venous leakage to 92 min in min in neurogenic pts) OS with drug (%) 88% (108/136) Satisfaction with auto-injector (%) 92% (111/136 participants) Other outcomes assessed: response of patients previously treated with one or more alternative therapies Withdrawals/drop-outs/loss to f/u, n (%): n=35 (30 never used injections and were removed) WDAE, n (%): 6 (4) TAE: reported for dose assessment + RCT phase: % of injections with at least one AE 65 vs. 68 vs. 27 (flushing 47 vs. 50 vs. 9; bruising in less than 8% of injections and pain experienced only on injection in 8% in CG alone; priapism in n=1 IG1 equal to 0.1% of 962 injections); AE experienced in 91% vs. 93% vs. 65% of pts SAE: 0 Ascertainment of outcomes assessed: Diary entries, F/u questionnaire
Earle (1990) ^165^ Funding source: NR | N screened = NR N randomized = 205 crossover design (1 & 2) IG1/IG2, n= 205 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: men with ED, (also included low testosterone men) Exclusion: NR Data reported for n=129 who completed the 1^st^ injection | Age, mean range: 52–59 y Co-morbidities: Alcohol >420 gm/wk: 20 Blood glucose: ▴ glucose in diabetics n=6, & normal glucose n=15 Previous ED treatment: NR Smoking status: 18 smokers 55 ex-smokers Body weight: NR | Concomitant medications: 80/129 (33 on hypotensive/ cardio-active medication) Duration of ED: NR Underlying disease: Low testosterone (<11nmol/L) n=11 Psychogenic ED: Affective psychosis 1 Physiologic ED: n=80 Vascular 51; Lower back injury: 2; Diabetes 26; Bowel tumor resection: 1 Mixed ED: NR Other: also other causes of ED, idiopathic n=35 | IG1: PgE_1_, Compressed base, massaged penis IG2: Papaverine, Compressed base, massaged penis IG1: Dose: 5 μg Duration: 5–10 s Frequency: once every mo for 2 mo Compliance: 83% for 1^st^ injection; 100/129 (78%) for 2^nd^ injection IG2: Dose: 18 mg Duration: as a Frequency: as a Compliance: as IG a Run In period: NR Wash out period: 1 mo F/u duration: 10–20 min post injection | Primary outcome results: Quality of erection, n (%): IG1 vs. IG2 No response: 0 vs. 5 (39) Partial erection: 95 (74) vs. 107 (83) Full erection: 34 (26) vs. 17 (13) (chi-square = 6.26, p<0.025) Attempts to intercourse on intervention, a vs. b Successful intercourse (4 wks): 40 (31%) vs. 43 (33%), chi-square = 0.077, (p > 0.05) Other outcomes assessed: self reported observations Withdrawals/drop-outs/loss to f/u: 76 (37% post initial IC); 29 (22%) dropout following 2^nd^ intervention WDAE: NR TAE: NR [AE Pain during injection: IG1: 11 (8.5%) IG2 6 (4.7%) Prolonged erection: < 8 hrs: 1in IG2 (no event in IG1)] SAE: NR Ascertainment of outcomes assessed: patient report
El-Saleh (1995) ^166^ Funding source: NR | N screened = NR N randomized = 16 (cross over) IG1/IG2/IG3, n = 16 ITT analysis used for primary outcome: No Inclusion: Use of PGE1 to obtain erection suitable for intercourse Exclusion: NR Result of this study is presented in graphs. The data could not be extracted for this table. | Age, mean (sd): 59 (7.7) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight, mean (sd): 82.73 (11.29), kg | Concomitant Medications, n: hypotensive drugs: 4 vitamins: 4 10 patients were on undisclosed prescribed medications Duration of ED, mean (range): 6.7 (2–16) y Underlying disease, n: Diabetes: 1 Multiple sclerosis: 1 Thyroidectomy: 1 Hx of musculoskeletal back injuries: 3 Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: PgE1 + digital compression by penile clamp IG2: PgE1 + hand compressin IG3: PgE1 with no compression IG1/IG3: Dose: mean (sd) 17.5 (16.5), range 2.5 to 50 μg (according to the dose used pre-trail) Duration: 3–5 s Frequency: total 3, once/d /tx Compliance: 100% IG2: Dose: NA (pressure = 100 mm Hg) Duration: 3.8–4.5 min Frequency: once Compliance: 100% Run In period: NR Wash out period: NR (min 3 d between any injections at home & clinic injection) F/u duration: NR | Primary outcome results: Erection (at least some degree of tumescence): 100% of pts; only 7/15 (47%) had response comparable to home injection result Presence of erection: no consistent evidence in favour of use of clamping or compression of any sort to obtain better erection Rating of erection in laboratory compared to erections at home: no consistent indication that clamp was more useful than being at home Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: n=1 (excluded from analysis due to withdrawal in IG1) WDAE NR TAE: NR SAE: NR Ascertainment of outcomes assessed: Patient perception, clinical palpation, RigiScan, pulse, BP
Floth A (1991) ^167^ Funding source: NR | N screened = NR N randomized = 87 (two cross over design studies) IG1 n = 49 IG2, n= 38 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: NR Exclusion: NR Data reported for IG1 (a vs. b) vs. IG2 (a vs. b) | Age, mean (sd): 51(13) vs. 53 (12) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: Diabetes in 9 (18.9 %) Psychogenic ED, n (%): 6 (12.3) vs. 4 (10.5) Physiologic ED: Arterial restriction: 32 (65.3) vs. 26 (68.4); venous leak: 8 (16.3) vs. 5 (13.2); neurogenic: 3 (6.1) vs. 3 (7.9); DM: 8 (16.3) vs. 1 (2.5) Mixed ED: Acknowledged but NR | IG1 a: Papaverine + phentolamine b: Papaverine + PgE_1_ IG2: a: PgE_1_ alone b: same as IG1b IG1 a: Dose: papaverine 7.5 mg + phentolamine 0.25 mg Duration: NA Frequency: once IG1 b/IG2 b: Dose: papaverine 7.5 mg + PgE1 5 μg Duration: NA Frequency: once IG2 a: Dose: PgE1 10 μg + papaverine 7.5 mg Du ration: NA Frequency: once Run In period: NR Wash out period: 2 d F/u duration: NR | Primary outcome: a vs. b Time to erection, mean (sd): IG1: 8.6 (4) vs. 8.2 (5) min IG2: 7.3 (3) vs. 8.3 (5) min Duration of erection, mean (sd): IG1: 178.5 (133) vs. 146.6 (131) min IG2: 109.3 (61) vs. 124.3 (111) min Quality of erection (objective), n (%): IG1, between arms p< 0.01 score 1–2: 12 (25) vs. 6 (12) score 3: 9 (18) vs. 5 (10) score 4–5: 28 (57) vs. 38 (78) IG2, between arms, p= 0.03 score 1–2: 3 (8) vs. 2 (5) score 3: 12 (32) vs. 8 (21) score 4–5: 23 (61) vs. 28 (74) (b more effective than a) Other outcomes assessed: Duplex Ultrasound Peak velocity flow (no data) Withdrawals/drop-outs/loss to f/u: NR WDAE: 0 TAE: NR (AE Prolonged erection: > 5 hrs IG1: 4 vs. 4; IG2: 0 vs. 4 Pain: IG1: 0 vs. 8 (16.3%); IG2: 13 (34.2%) vs. 7 (18.4%) SAE: NR Ascertainment of outcomes assessed: Researcher observed erection scale 1–5:
Fu (2004) ^168^ Funding source: NR | N screened = NR N randomized = 42 cross over IG1/IG2, n = 42 CG, n= NA ITT analysis used for primary outcome: No Inclusion: normal range of serum testosterone, PRL, estradiol, FSH, LH and glucose Exclusion: neurogenic or endocrinopathic ED | Age, mean (range): 43.5 (27–65) yr Race: 100% Chinese Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: sodium nitroprusside IC IG2: papaverine + phentolamine by IC IG1: Dose: sodium nitroprusside 300 micrograms Duration: NA Frequency: once Compliance: NR IG1: Dose: papaverine 30 mg + phentolamine 1mg Duration: NA Frequency: once Compliance: NR Run In period: NR Wash out period: 1 wk F/u duration: NR Other: [underlined: N of pts reported slightly different in the report] | Primary outcome results: Erection characteristics: in IG1: Length: ▴ 4.75 (1.45) cm Circumference ▴ 2.59 (1.65) cm Rigidity: all patients scored >10, with 25 >100 Duration of erection (scores >100): 24.23(7.96), range 15–45 min IG2: Length ▴ 4.00 (1.80) cm Circumference ▴ 2.71 (2.05) cm Rigidity: all patients scored >10, with 28 >100 Duration of erection (scores >100): 37.68 (15.36), range 20–55 min Other outcomes assessed: NA Withdrawals/drop-outs/loss to follow: NR WDAE: 0 TAE: IG1: 0; IG2: 3 had priapism, 15 had local pain SAE: 0 Ascertainment of outcomes assessed: physician assessment of outcomes
Garceau (1996) ^169^ Funding source: NR | N screened = NR N randomized = 54 IG/CG, n = 54 ITT analysis used for primary outcome: Y Inclusion: men with ED, previous PgE1 treatment Exclusion: Hx priapism; Sickle Cell anemia or trait, Untreated endocrine disorders, Cavernosal fibrosis; anatomical deformation of penis, Peyronie's disease, thyroid condition causing ED; onset of acute illness, hx of Sexually Transmitted dx ≤ 6 mo, using hormonal or investigational medications, Previous use of IC to tx ED Note: baseline pts data reported for pooled data (n=365) of this RCT (n=54) and a dose titration study of n=294 | Age, mean (range): 48.9 (21–75) y Co-morbidities: NR Previous ED treatment: 100% PgE_1_ users Smoking status: NR Body weight: mean: 71 (range: 45 – 121) kg | Concomitant medications: NR Duration of ED, mean (range): 3.8 y (2 – 35 mo) Underlying disease: NR Psychogenic ED: 101 (27.7%) Physiologic ED: Vascular: 150 (41.1%) Neurogenic: 10 (2.7%) Mixed ED: 74 (20.3%) Other: 30 (8.2%) other causes | IG1: PgE_1_ (in three formulation: aqueous injection, sterile powder, or Prostin VR ^(R)^) CG: placebo IG: Dose: 2.5, 5, 10 or 20 μg (randomized based on past dose, <10 mg to 2.5 or 5 μg; >10 μg to either Duration: NR Frequency: 3 (one injection of each formulation at assigned dose if randomized to IG) Compliance: NR CG: Dose: NR Duration: NR Frequency: once (?) Compliance all: NR Run In period: 3 wks (no PgE1 injections) Wash out period: NR F/u duration: NR | Primary outcome results: Optimal erectile response, n/N (%): 2.5 μg: 2/13 (15%) 5 μg: 10/16 (63%) 10 μg: 4/10 (40%) 20 μg: 10/15 (67%) CG: NR Other outcomes assessed: Optimal erectile response, latency of erection, duration of erection, time to complete de-tumescence, also reported for pooled population Withdrawals/drop-outs/loss to f/u: 1in due to pain post IC injection WDAE: NR TAE: NR AE: NR [Pooled data (n=365): 45 (12%) of pts experience drug related (as reported by authors) events; pain: 53 episodes in 39 (11%) pts] SAE: 0 Ascertainment of outcomes assessed: a five-point scale ranging from 0 (“not effective”) to 4 (“very effective”)
Gherchiu (1996) ^170^ Funding source: NR | N screened = NR N randomized = 11 (cross over) IG1/IG2, n = 11 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: pts with previous self injection of PGE1 at home Exclusion: NR | Age, range: 44–72 y Co-morbidities: NR Previous ED treatment: PGE1 Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: fast injection of Pg E1 at IG2: slow injeciton of PgE1 IG1/2: Dose: NR (same does as at home use); injected in 5 s in IG1, and in 60 s in IG2 Duration: NA Frequency: single injection Compliance (%): 100% Run In period: NR Wash out period: 7 d F/u duration: NR | Primary outcome results: IG1 vs. IG2, mean (sd): Intensity of pain: 1.5 (1.8) vs. 0.6 (1.5), p = 0.04 Duration of pain: 29 (70.5) vs. 11 (27.5), p = 0.11 Note: n=1 experienced pain for 250 min (IG1), and 65 min (IG2); n=10 experienced pain for 25 min or less) Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE: NR (AE pain, n (%): n=8: 26(55%) vs. 2 (18%) SAE: NR Ascertainment of outcomes assessed: Intensity of pain by 10 point Likert scale (0 =no pain; 10 =worse pain)
Godschalk (1994) ^171^ Funding source: NR | N screened = 28 N randomized = 15 IG/CG, n = 15 (crossover design; 3 phases: phase I double blind; phase II and III nonblind. Non responders from phase I moved to phase II, responders of phase &II move to phase III) ITT analysis used for primary outcome: NR Inclusion: ED of all causes Exclusion: major illness within previous 6 mo; uncontrolled diabetes or hypertension; hypogonadism; laboratory value ≥ 25% above or below normal range; previous IC injections for treatment of ED Phase II / III may not be randomized | Age, mean (sd): 55.8 (9.2) Race (%): white 7, black 7, Hispanic 1 Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: mean number of pts (sd) 2.7 (1.3) Duration of ED (yr): 7.61 (SD 9.85) Underlying disease: NR Psychogenic ED: 0 Physiologic ED: 15 Mixed ED: 0 | IG1: PgE_1_ CG: placebo IG:/CG Dose: Phase I: 0 (placebo) 2.5, 5, 7.5 and 10 μg Phase II: 12.5 (15–50) μg Phase III: mainenance dose Duration: 8 wks [4 wks (I & II); 4 wks (III)] Frequency: 2/wk; total Phase I=II: 10 doses Run In period: NR Wash out period: 0.5 wk F/u duration: 120 min post dosing | Primary outcome results: All means approximate Penile rigidity (%), from scale of 0–100%, phase I: IG, 2.5 μg 30%; 5 μg 47%, 7.5 μg 38%; 10 μg 43%(Overall in 5–10 μg dose: 40%) vs. CG: 7% Full erection (60% rigidity) or experienced intolerance in phase I, n: 6/15 (moved to phase III) Phase II, (n=8): Adequate erection, n: 4/8 (entered phase III) Phase III, (n=10): Partial or full erection, in 85% Other outcomes assessed: Rigidity (absent, partial or full) as assessed by palpation Withdrawals/drop-outs/loss to f/u: n=1 in phase II WDAE: 0 TAE: NR SAE: 0 Ascertainment of outcomes assessed: RigiScan™ Rigidity Assessment System
Godschalk (1996) ^172^ Funding source: NR | N screened = 13 N randomized = 10 (cross over) IG1/IG2, n = 10 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: 18–75 yr with ED who had experienced penile pain after at least 70% of IC PgE1 self injections at home Exclusion: recent major illness, uncontrolled hypertension, or diabetes, a hx of priapism, Peyronie's plaques or laboratory abnormalities greater than 25% above or below accepted normal ranges, use of analgesics | Age, range: 18–75 yr Co-morbidities: NR Previous ED treatment: Pg E1 Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: PgE1 + sodium bicarbonate (alkaline) IG2: PgE1 alone (acidic) IG1: Dose:PgE1 20 μg+ 42 mg/ml sodium bicarbonate, to reach PH of > 7 Duration: 2 d Frequency: single dose Compliance: 100% IG2: Dose: PgE1 20 μg Duration: as IG1 Frequecy: single dose Compliance: 100% Run In period: NR Wash out period: at least 1 d F/u duration: NR | Primary outcome results: IG1 vs. IG2, mean (sd): Degree of pain: 3.4 (2.9) vs. 2.7 (1.9), (p = 0.27) Duration of penile pain: 50.9 (45.3) vs. 56.9 (59.5) min, NS (p=0.37) Frequency of pain: ▾in in IG1 (not sign.) Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: n=0 WDAE n=0 TAE: NR [AE, n (%): pain, IG1 vs. IG2, 70% vs. 80%; n=6 experienced pain with both injections] SAE: NR Ascertainment of outcomes assessed: Pain and its duration by pts filled questionnaire Severity of pain by 10 point Likert scale (0=no pain to 10=- worst pain)
Gontero (2003) ^173^ Funding source: NR | N screened = 95 N randomized = 79 (parallel) IG1, n = 36 IG2, n= 37 CG, n= NA ITT analysis used for primary outcome: No Inclusion: Non-nerve sparing radical prostatectomy, diagnosis of localized prostate cancer, completion of IIEF Exclusion: NR | Age, mean: 65 y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%) Adjuvant hormones; IG13 (8) vs. IG2 4 (11) Radiotherapy; IG1= IG2 4 (11) Duration of ED: NR Underlying disease: 100% Prostate cancer (palpable tumor) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: PgE1 (early intervention) IG2: PgE1 (delayed intervention) IG1: Dose: 20 mg Duration: NA Frequency: once, 1–3 mo post operative Compliance: 100% IG2: Dose: 20 mg PgE1 Duration: NA Frequency: once, 4–12 mo post operative Compliance: 100% Run In period: NR Wash out period: NR F/u duration: NR | Primary outcome results: IG1 vs. IG2 Grade 3–4 erection post operatively, (%): IG1 80% vs. IG2 37% Mean visual analog scale (rating of discomfort with 0 = no pain and 10 maximal pain): 3.58 vs. 2.58 Other outcomes assessed: Pathological stage, Gleason score, concomitant adjuvant treatment; Peak systolic velocity < 30 cm/s (n/grp): 8/36 (22.2%) vs. 19/37 (51.3%) Withdrawals/drop-outs/loss to f/u: n=6 (2 excluded for high scores on IIEF, 4 refused to undergo Doppler ultrasound) WDAE: 0 TAE: NR [AE prolonged erection, in n=3 (IG1)] SAE: 0 Ascertainment of outcomes assessed: IIEF, Dynamic colour Doppler ultrasound, Grading of erection (0–4: 3=suboptimal rigidity, sufficient for penetration; 4= full rigidity for at least 20 min), Visual Analog Scale Score
Kattan (1991) ^174^ Funding source: NR | N screened = 54 N randomized = 50 Crossover design IG1/IG2, n = 50 split in two grps (1 & 2) of 25 to receive 1^st^ intervention and then switched to the 2^nd^ intervention CG, n = NA ITT analysis used for primary outcome: NR Inclusion: men with vasculogenic impotence who failed Papaverine Exclusion: NR | Age, mean (sd): 57.08 (7.41) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease (diagnosis) (N or % of diseased/grp): NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: PgE_1_ IG2: Papaverine IG1: Dose: 20 μg in 2 ml volume Duration: NA Frequency: Single Compliance: 100% IG2: Dose: 60 mg in 2 ml volume Duration: NA Frequency: single Compliance: 100% Run In period: NR Wash out period: 1 wk= half life of drug F/u duration: NR | Primary outcome results: Researcher observed quality of erection, IG1 vs. IG2 Positive response: 34% vs. 2% (12% responded to both treatments) Satisfactory erection, (%): 46% vs. 14% Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: 4 drop outs post first IC WDAE: 0 TAE: NR (Aepainat IC site < 10 min, (% of pts): 47% vs. 6%; Dizziness + headache: 2% vs. 4%) SAE: NR Ascertainment of outcomes assessed: Researcher observed quality of erection Partial or complete response vs. no response
Kattan (1995) ^175^ Funding source: NR | N screened = NR N randomized = 25 (crossover design) IG1/IG2, n = 25 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: NR Exclusion: Hx of MI; uncontrolled BP | Age, mean (sd): 53, range 40–60 Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease, n: diabetes 17, heavy smoking (> 1 pack/day) 9, on antihypertensives 2, low serum testosterone levels 3, Peyronie's disease 1 Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: PgE_1_ IC IG2: PgE_1_ plus lidocaine hydrochloride IC IG1: Dose: 20 μg (+ manual sexual stimulation for 10 min after injection) Duration: NR Frequency: 1 dose Compliance: NR IG2: Dose: 20 μg PgE_1_ + 1 cc lidocaine 1% (+ manual sexual stimulation for 10 min after injection) Duration: NR Frequency: 1 dose Compliance: NR Run In period: NR Wash out period: 1 wk F/u duration: NR | Primary outcome results: Erection assessed by investigator on 4-point scale from 0 (none) to 3 (normal), (n) Grade 0: 2 vs. 2 Grade 1: 14 vs. 6 Grade 2 (adequate): 6 vs. 11 Grade 3: 0 vs. 3 Adequate erection, (% of pts): 27% vs. 64% Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: n=3 (2 due to AE) WDAE: 3 TAE: NR, (AE: pain in 22 (86% vs. 10 (45%); local edema at site of injection 1(5%) vs. 0) SAE: NR Ascertainment of outcomes assessed: NA
Kunelius (1998) ^176^ Funding source: NR | N screened = 30 N randomized = 30 (cross over) IG1-3/CG, n = 30 ITT analysis used for primary outcome: No Inclusion: NR Exclusion: NR | Age, mean: 55 (21–71) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant Medications: NR Duration of ED: NR Underlying disease: NR Physiologic ED: NR Psychogenic ED: NR Mixed ED: NR | IG1: papaverine IG2: PgE1 IG 3: moxisylyte CG: placebo IG1: Dose: 40 mg (1 mL) Duration: NA Frequency: once /visit Compliance: 100% IG2: Dose: 20 μg Duration: NA Frequency: once /visit Compliance: 100% IG3: Dose: 20 mg Duration: NA Frequency: once /visit Compliance: 100% CG: Dose: 1 mL saline Duration: NA Frequency: once /visit Compliance: 100% Run In period: NR Wash out period: NR F/u duration: 15 min post injection | Primary outcome results: IG1 vs. IG2 vs. IG3 vs. CG Tumescence: no difference between the agents Rigidity (maximal at tip (%▴): I20.7 vs. 33.9 vs. 14.2 vs. 0 Rigidity (maximal at base (%▴): 16.8 vs. 34 vs. 14.2 vs. 0 Clinician rating of erection, patients with grade 4/5, (%): 10 vs. 40 vs. 7 vs. NR Mean Duration of Erection (min) 13.4 vs. 40.2 vs. 6.5 vs. 0 Other outcomes assessed: BP, pulse rate, patient satisfaction with erections Withdrawals/drop-outs/loss to f/u: 0 WAED: 0 TAE: NR (AE: prolonged erection of > 2 hrs: 6 (20%); IG1 n=2, IG2 n=3; IG3 n=1 SAE: 0 Ascertainment of outcomes assessed: RigiScan device; pts filled questionnaire; degree of erection 0–5 (4&5 sufficient for penetration)
Linet (1996) ^177^ Funding source: Upjohn Company | N screened = NR N randomized = 296 (parallel design) IG1 n = 57 IG2, n = 60 IG3, n = 62 IG4, n = 58 CG n = 59 ITT analysis used for primary outcome: Y Inclusion: ED ≥ 4 mo Exclusion: penile deformity (including fibrosis); hx of priapism; sickle-cell trait; recent major illness; uncontrolled DM or hypertension; major psychiatric disorder; human immunodeficiency virus infection or other transmittable disease; heavy smoking (> 40 cigarettes/day); endocrine causes of ED | Age, mean (range): 54, (21–74) y Co-morbidities: NR Previous ED treatment: IC treatment 7 (2%) Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: 39 (13%) Physiologic ED: Vasculogenic 130 (44%) Neurogenic 39 (13%) Mixed ED: 86 (29%) | IG1-4: PgE1 (alprostadil) CG: placebo IG1-4: Dose: 2.5 (IG1), 5 (IG2), 10 (IG3) or 20 (IG4) μg Duration: NA Frequency: 1 dose Compliance: 100% CG: Dose: placebo Duration: NA Frequency: 1 dose Compliance: 100% Run In period: NR Wash out period: NR F/u duration: NR | Primary outcome results: % of pts with Radial rigidity clinician assessment) (RigiScan data: / ≥ 70% rigidity at tip or base of penis lasting ≥ 10 min) IG: 2.5 μg approx. 17% (21%) 5 μg approx. 27% (31%) 10 μg approx. 45% (27%) 20 μg approx. 50% (48%) CG: 0 (0) Note: above numbers extracted from bar graph Duration of erection (mean) 2.5 μg, 12 min; 20 μg, 44 min, p<0.025 Other outcomes assessed: % of patients with satisfactory sexual activity (masturbation, and intercourse); Withdrawals/drop-outs/loss to f/u: 0 WDAE 0 TAE: NR (AE: IG only: Penile pain 54 (23%); priapism 6 ( SAE: n=1 death (reported to be unrelated to study drug) Ascertainment of outcomes assessed: RigiScan™ Ambulatory Rigidity and Tumescence System
Mahmoud (1992) ^178^ Funding source: NR | N screened = NR N randomized = 52 Cross over design (intervention a & b) IG1/IG2, n = 52 CG, n = NR ITT analysis used for primary outcome: NR Inclusion: pts who consulted clinic for erectile failure Exclusion: NR Notes 1-on eligibility: to compare drug safety 8 patients with hx of priapism with Papaverine IC were included in PgE1 arm & excluded from Papaverine arm 2-This trial includes n=2 with SCI 3- pts were categorized by subgroups according to probable cause of ED dx at baseline | Age, mean (sd): mean 48.6 (10.4) y Race: 100% Egyptian Co-morbidities: NR Previous ED treatment: Papaverine hydrochloride in 8 Smoking status: NR Body weight: NR | Concomitant medications: NA Duration of ED, mean (sd): 2.98 (1.19) y, range 0.7 – 6 y Underlying disease: (> 5 yr): Hypertension 8; Diabetes 7; diabetes + hypertension 3; Transverse Myelitis:2 SCI: 2 Radical cystectomy:1 Hyperprolactemia:5 Psychogenic ED: 10 (19%) Physiologic ED: Vasculogenic 24 (46%) Neurogenic ED 5 (10%) Endocrinological 5 (10%) Mixed ED: NR; Undetermined cause 8 (15%) | IG1: PgE_1_ IC with hand pressure around base and massage of shaft. IG2: Papaverine hydrochloride IC as above IG1: Dose: 20 μg/ml Duration: NA Frequency: Single IG2: Dose: 30 or 60 (if failed with low dose) mg/ml Duration: NA Frequency: Single Compliance all grps 100% Run In period: NR Wash out period: 3 d interval between injections F/u duration: 24–48 hrs post IC unless priapism then seen at 3hrs | Primary outcome results: IG1 vs. IG2, n (%) Positive response in: 42 (81%) vs. 33 (63%) Negative response: 10 (19%) vs. 19 (37%) Results also reported for subgroup based on dx (i.e. underlying dx) Erection duration, mean (sd): 2.5 (0.4) hrs vs. 2.52 (0.72) hrs Time to full erection, mean (sd): 15.4 (5.4) vs. 10 (3.7) min Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: NR (AE: Penile pain: Tolerable: 6 (11.5%) vs. 13 (25%) Intolerable: 0 vs. 4 (7.7%) SAE: Priapism: 0 Ascertainment of outcomes assessed: Clinician measures of erection duration/angle; also rating of erections (positive/good ≥ 2hrs at nearly 90 degrees; negative/poor: < 2hrs at ≤ 90 degrees; negative/absent: no tumescence; Priapism:> 3 hrs)
Mancini (2004) ^179^ Study a, and b Funding source: NR | N screened = 97 N randomized = 56 (36 vasculogenic (a) & 20 non-vasculogenic (b) pts randomized independently into 3 & 2 grps respectively) a: Vasculogenic IG1a n = 12 IG2a: n = 12 CG, n = 12 b: Non-vasculogenic IG1b, n = 10 IG2b, n- = 10 ITT analysis used for primary outcome: NR Inclusion: pts with atherosclerosis, and ED verified with IIEF Questionnaire; duration of ED no more than 3 mo in duration Exclusion: Organic cause of ED apart from vasculopathy | Age, mean range: 54.6–59.6 y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: < 3 mo Underlying disease: IG1a & IG2a & CG: vasculogenic IG1b, IG2b: not vasculogenic Psychogenic ED: NR Physiologic ED: 56 Mixed ED: NR | IG1: PgE1 (alprostadil) IG2: oral Sildenafil: CG Placebo: (oral) IG1(a & b): Dose: 5–20 ug (dose assessment based on 1–3 injection to verify the dose inducing a full erction lasing 10 min) Duration: 1 mo Frequency: 1 /wk Compliance: 100% IG2 (a & b): Dose: 25 mg Duration: 1 mo Frequency: every night Compliance: 100% CG: Dose: placebo Duration: 1 mo Frequency: every night Compliance: 100% Run In period: 1 wk (dose assessment phase IG1 a & b) Wash out period: 1 wk F/u duration: 7d post last tx | Primary outcome results: Peak Systolic Velocity, mean (sd): IG1a: non sign. from baseline IG1b: pre 21(4) post 26(7). IG2a & b: non sign. from baseline CG: pre 20(5) post 28(9) Erectile rigidity (IIEF), mean (sd), pre vs. post treatment: IG1a: 15 (5) vs. 22 (3) IG1b: 13 (7) vs. 21 (9) IG2a: 13 (4) vs. 18 (3) IG2b: 11 (8) vs. 12 (11) CG: 15 (5) vs. 20 (6) Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: n=1 in IG1a, excluded in dose assessment phase (no response to PgE1 injection) WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: Duplex Sonography examination, IIEF-15 questionnaire
Martinez-Piñeiro (1995) ^180^ Funding source: NR | N screened = NR N randomized = 105 (crossover design, intervention 1 and 2) IG1, n = 10 IG2, n = 60 IG3, n = 35 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: ED Exclusion: NR | Age, mean, (range): 53.6 (27–79) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1-3: PgE_1_ IC [as first intervention (n=58); as second intervention, (n=57)] + one of 3 concentrations of sodium nitroprusside (SN) IG1: Dose: 20 μg cross over to 100 μg SN diluted in 5% dextrose Duration: NA Frequency: 1 dose of each Compliance: 100% IG2: Dose: 20 μg cross over to 300 μg SN diluted in 5% dextrose Duration: NA Frequency: as IG1 Compliance: 100% IG3: Dose: 20 μg cross over to 400 μg SN Duration: NA Frequency: as IG1 Compliance, all: 100% Run In period: NR Wash out period: 1–7 d F/u duration: NR | Primary outcome results: sodium nitroprusside 100 μg was not effective in producing erections Erectile response, % of pts, [no erection/ partial rigidity/ full rigidity]: IG2 (PgE1 vs. 300 μg): [25/ 55/ 20] vs. [33/ 52/ 15] IG3 (PgE1 vs. 400 μg): [29/ 51/ 20] vs. [40 / 46/ 14] Duration of erection: (PgE1 vs. 300 μg vs. 400 μg), mean (range): 88.5 (5–220) vs. 51(5–129) vs. 42 (5–129) min Other outcomes assessed: Time required to initiate tumescence; patient satisfaction Withdrawals/drop-outs/loss to f/u: n=0 WDAE: 0 TAE: NR AE, n (%): IG1 vs. IG2 vs. IG3PgE1 vs. SN 100 μg vs. SN 300 μg vs. SN 400 μg: Pain during injection: 7 (7) vs. 0 vs. 0 vs. 0; Dizziness: 4 (4) vs. 1 (10) vs. 5 (8) vs. 1 (3); haematoma: 1 (0.9) vs. 0 vs. 1 (2) vs. 0 SAE: 0 Ascertainment of outcomes assessed: clinical & pts assessment
Montorsi (1997) ^181^ Funding source: NR | N screened = NR N randomized = 30 IG, n = 15 CG, n = 15 ITT analysis used for primary outcome: NR Inclusion: men with clinically localized prostate cancer stage B1 or B2, Gleason sum 7 or greater, prostatic specific antigen cell less than 20 ng Exclusion: NR | Age, mean (range): 62 (49–68) yr Co-morbidities: NR Previous ED treatment: NA Smoking status: NR Body weight: NR Other: clinical stage: B1 n=18, B2 n=12; Mean Gleason sum at biopsy = 4.2 (3–6); mean preoperative PSA = 9.2 (2.1–18.2) ng/ml | Concomitant medications: NR Duration of ED: NA Underlying disease: Prostate cancer Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: CG: no post-operative ED n=2 (13%) | IG: PgE1 (alprostadil), self injection CG: No treatment IG: Dose: 2.5–14 μg (mean dose used 8 μg) Duration: 12 wks Frequency: 3 times/wk, total 36 injections Compliance: 80% CG: Dose: NA Duration: as IG Frequency: NA Compliance: all Run In period: 1 mo Wash out period: NA F/u duration: 12 wks | Primary outcome results: IG1 vs. CG Recovery of spontaneous injections at 3 mo, n (%): Full: 8 (67) respond (needed injections once/4 time) vs. 3 (20) (p<0.01); Partial respond: 3 (33) (needed to inject more than 50% of times) vs. 10 failures (67) Color Doppler test (normal hemodynamics in n=10 (83%) (all responders, 2 partial responders) vs. n=2 (all responders); cavernous veno-occlusive dysfunction n=2 (all partial responders) vs. n=8 (failures) CG: cavernous artery insufficiency n=2 (17%) Other outcomes assessed: Nocturnal erections (during a 3-night period); hemodynamic results Withdrawals/drop-outs/loss to f/u, n: 3 vs. 0 WDAE: IG: n=3 (20%), reduced sexual interest (n=2), penile nodule (n=1) TAE: IG1: n=3 with at least one AE: one event of cavernous haematoma in n=2 (13%); one event of prolonged erection in n=1 (6%); CG: no AE SAE: NR Ascertainment of outcomes assessed: Sexual hx, physical examination; hemodynamics post μg alprostadil + genital & audiovisual sexual stimulation; RigiScan
Montorsi (1998) ^182^ Funding source: NR | N screened = NR N randomized = 20 (crossover design to interventions a & b) IG n= 20 CG n= NA ITT analysis used for primary outcome: NR Inclusion: pts who failed to produce an erection with 1 dose of PgE1 at initial session post randomization Exclusion: NR | Age, mean (range): 54 (42–66) y Co-morbidities (unrelated to disease): NR Previous ED treatment: NR Smoking status: 10 (50%) Body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 0.9, (0.6–3.2) y Underlying disease, n (%): diabetes 5 (25%), hypertension 4 (20%), coronary artery occlusive disease 4 (20%), hyperlipidemia 4 (20%) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | Intervention: a) PgE1 (alprostadil) b) PgE1& genital + audiovisual sexual stimulation IG a: Dose: 10 μg Duration: NA Frequency: 2 doses 10 min apart Compliance: 100% IG b: Dose: 10 μg Duration: NA Frequency: 1 dose followed by stimulation 10 min later Compliance: 100% Run In period: NR Wash out period: 1 wk between sessions F/u duration: NA | Primary outcome results: 5-min period of max response (penile rigidity & tumescence-circumferential expansion), expressed as area under the curve, mean (sd) IGa vs. IGb Tumescence base 60 (3) vs. 70 (2) Tumescence tip 28.0 (2) vs. 35 (1) Rigidity base 53 (2) vs. 66 (2) Rigidity tip 33 (2) vs. 40 (1) Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: 5 WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: RigiScan™ Rigidity Assessment System
Moriel (1993) ^183^ Funding source: NR | N screened = NR N randomized = 38 (cross over) IG1/IG2, n = 19 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: ED Exclusion: NR | Age, mean (range): 55 (23–77) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: NA | IG1: Trimix + sodium bicarbonate IG2: Trimix CG: NA IG1: Dose: 6 mg papaverine, 100 μg phentolamine + 10 μg PgE_1_ (trimix), 7.5% sodium bicarbonate (0.03 mEq) Duration: NA Frequency: 1 dose Compliance: 100% IG2: Dose: trimix as IG1 Duration: NA Frequency: 1 dose Compliance: 100% Run In period: NR Wash out period: NR F/u duration: NR | Primary outcome results: Erectile response, n (%) with positive response: IG1 15 (79%) vs. IG213 (68%) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: Patients' experience of discomfort or pain: IG1: 1 (5%); IG2: 11 (58%) SAE: 0 Ascertainment of outcomes assessed: NR Other: Authors don't state how erectile response was evaluated.
Ogrinc (1995) ^184^ Study a Funding source: Upjohn Company | N screened = NR N randomized = 153 (4-way cross over) IG, n = 153 (4 various doses) CG, n = NR ITT analysis used for primary outcome: NR Inclusion: ED ≥ 4 mo Exclusion: anatomical deformation of penis; penile fibrosis; hx of priapism; recent onset of major disease; uncontrolled diabetes or hypertension; major psychiatric disorder; excessive cigarette use; use of other investigational agents. Previous use of IC vasoactive agents permitted. | Age, range: 23–69 y Race: NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: PgE1 (alprostadil) in four doses CG: placebo IG: Dose: 2.5, 5, 7.5 & 10 μg Duration: NR Frequency: single injection / dose in a randomized order Compliance: 100% CG: Dose: placebo IC Duration: NR Frequency: as IG Compliance: 100% Run In period: NR Wash out period: NR F/u duration: NR | Primary outcome results: Erection response (full, partial or none), IG vs. CG: NR Positive response (% of total injections): by clinical/ evaluation: 17% By RigiScan 15% Other outcomes assessed: Agreement vs. disagreement between clinical & RigiScan monitoring: —Using 70% axial rigidity as criteria: agreement: 418/521 injections (80%)/ Disagreements: 17% present by clinical evaluation only; 3% erection present by RigiScan only —Using 60% axial rigidity as criteria: 422/521 injections (80%)/ 11% Sensitivity, RigiScan = 47.6% (80/168 with clinical response) Specifity, RigiScan: 95.8% (338/353 injections) Withdrawals/drop-outs/loss to f/u: n=25 WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: RigiScan™ & clinical (palpation) evaluation
Ogrinc (1995) ^184^ Study b Funding source: Upjohn Company | N screened = NR N randomized = 296 (parallel design) IG, n = 237 CG, n = 59 ITT analysis used for primary outcome: NR Inclusion: ED ≥ 4 mo Exclusion: anatomical deformation of penis; penile fibrosis; hx of priapism; recent onset of major disease; uncontrolled diabetes or hypertension; major psychiatric disorder; excessive cigarette use; use of other investigational agents. Previous use of IC vasoactive agents permitted. | Age, range: 21–74 y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): NR Underlying disease (diagnosis) (N or % of diseased/grp): NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: IC PgE1 (alprostadil) in four various doses CG: IC placebo IG: Dose: 2.5, 5, 7.5 or 10 μg Duration: NR Frequency: single injection Compliance: NR CG: Dose: placebo Duration: NR Frequency: 1 dose Compliance: NR Run In period: NR Wash out period: NR F/u duration: 2 hr | Primary outcome results: Erection response (full, partial or none), 59 non response in CG (excluded from study) Positive response (% of total injections): by clinical/ evaluation: 11% By RigiScan: 23% Other outcomes assessed: Agreement vs. disagreement between clinical & RigiScan monitoring: —using 70% axial rigidity as criteria: agreement: 184/231injections (49.6%) disagreements: .11.3% erection present for clinical evaluation only; 9% erection noted by RigiScan criteria only —using 60% axial rigidity as criteria: agreement: 182/231 injections (79%) disagreements: 5.6% erection noted by clinical not RigiScan; 16% erection noted by RigiScan only Sensitivity, RigiScan = 67% (53/79 with clinical response) Specifity, RigiScan: 82% (131/152 injections) Withdrawals/drop-outs/loss to f/u: 6 (all IG) WDAE NR TAE: NR SAE: NR Ascertainment of outcomes assessed: RigiScan™ Rigidity Assessment System, & clinical (palpation) evaluation
Porst (1993) ^185^ Funding source: NR | N screened = NR N randomized = 40 crossover design, a & b IG1, n = 40 IG2, n = non-randomized grp, nonresponders of IGa+ IGb: 5 ITT analysis used for primary outcome? No Inclusion: men with ED, age 23–78 y (eligibility criteria not described in detail) Exclusion: NR This study a diagnostic evaluation of corpus cavernosal function | Age, mean (range): 55.9 (23–78) Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease, n (%): Diabetes 6 (15) Coronary heart disease 5 (12.5); hypertension: 9 (22.5); occlusive artery disease of lower limbs: 3 (7.5); cerebral infarction: 2 (5); post transurethral prostatectomy: 5 (12.5); radical prostatectomy: 2 (5 Rectum amputation: 1 (2.5) Psychogenic ED: 60% Physiologic ED: 40% Mixed ED: NR | IG1: PgE_1_ IG2: nitric oxide donor linsidomine IG1: Dose: 20 μg Duration: NA Frequency: once Compliance (%): 100 IG2: Dose: 1 mg Duration: NA Frequency: once Compliance (%): 100 Run In period: NR Wash out period: ≥ 48 hrs between dose F/u duration: NR | Primary outcome: ▴ peak flow: averaged 1/3 less in IG1 vs. IG2 [underlined: With < 30 cm/sec, in right / left arteries: Pathological values (%):] IG1= 17.9% / 17.9 % IG2 a= 64.1% / 56.4% IG2 b: no erection observed in 5 (100%) [underlined: Patient reported effectiveness of intervention, n (%)] IG2 > effective IG1: 0 (0%) IG1= IG2: 4 (10%) IG1 slightly superior IG2: 6 (15%) IG1 Moderately superior IG2: 8 (20%) IG1 much superior IG2: 22 (55%) [underlined: Researcher rated erection:] IG1 vs. IG2: No erection: 0 vs. 3 (7%) Tumescence: 7 (17.5%) vs. 23 (57.5%) Semirigid: 7 (17.5%) vs. 9 (22.5%) Full: 26 (65%) vs. 5 (12.5%) Other outcomes assessed: peak systolic velocity Withdrawals/drop-outs/loss to f/u: 1 (2.5%) not included in analysis WDAE: NR TAE: Unpleasant tenseness or pain in penis: 17.5% Vs. NR Moderate/severe headache: NR vs. 7.5% SAE: NR Ascertainment of outcomes assessed: clinician and pts reported erection outcomes
Roy (1990) ^186^ Funding source: NR | N screened = NR N randomized = 24 (3 × 3 factorial design, crossover study with assigned order of tx) IG1 & 2, n = 24 CG, n = 24 (same grp as IG) ITT analysis used for primary outcome: NR Inclusion: Non vasculogenic ED; Seeking treatment in urology clinic (nocturnal penile test was Exclusion: Penile BP index < 0.85 Outcomes reported for IG 1 vs. IG2 vs. CG | Age, range: 50–70 y Co-morbidities: NR Previous ED treatment: 4 previously papaverine 30 to 60 mg Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): NR Underlying disease: NR Psychogenic ED: Some psychogenic (no data) Physiologic ED: Diabetes (no data) Neurogenic (no data) Mixed ED: NR | IG1: Vasoactive Intestinal peptide (VIP) IC, low dose + compressed penile base (CPB) for 1 min IG2: VIP, high dose + CPB CG: Placebo +CPB IG1: Dose: 200 pmol in 1 ml volume Duration: 1 wk Frequency: once/ wk IG2: Dose: 400 pmol in 1 ml volume Duration: 1 wk Frequency: once/ wk CG: Dose: 1 ml saline Duration: 1 wk Frequency: once/ wk Compliance all grps: 100% Run In period: NR Wash out period: 1 wk F/u duration: 3 wks | Primary outcome results: Penile length increase by tx, mean %: 14.5 vs. 20.8 vs. 11(CG < IG1< IG2, p= 0.01) Diameter increase, mean %: 8.5 v. 13.7 vs. 3.9 (CG < IG1< IG2 p= 0.001) Penile rigidity score, mean: 1.3 vs. 1.4 vs. 1.3 (CG vs. IG1vs. IG2 p=0.056) Above parameters also reported by time (i.e. wk1, wk2, wk3) Repeat exposure to CG, IG1, IG2 ▾ diameter over time p=0.001 Repeat exposure to CG, IG1, IG2 ▾ rigidity over time p=0.008 Rigidity obtained: 0 vs. 0 Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: NR SAE: NR Ascertainment of outcomes assessed: Observer measurements; Rigidity: 15 min post treatment with scale 1-1 (no rigidity to full rigidity):
Sandhu (1999) ^187^ Companion: ^164^ Funding source: Senetek plc | N screened = 304 (dose assessment phase) * N randomized = 240 [cross over, intervention (a and b); and placebo] IG, n = 240 (133 phase II, maintenance phase) ITT analysis used for primary outcome: yes Inclusion: pts with ED ≥ 1 y in duration, ≥ 18y, currently in stable heterosexual relationship Exclusion: overt psychogenic aetiology, ability, any known systemic disease which produces overall weakness (other exclusion criteria is listed in the report) *Note: non responders to the non randomized dose assessment phase (details not reported in this table) entered into phase I, the result of which reported in this table | Age, mean (range): 58.5 (27–79) y Co-morbidities: NR Previous ED treatment: IC Alprostadil: 106 IC Papaverine/ phentolamine: 45 Other (Yohimbine, vacuum devices): 32 Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: atherogenic (n=58), DM (n=53), neurogenic (n=3), mixed Psychogenic ED: 0 Physiologic ED: 135 Mixed ED: 152 | IG: vasoactive intestinal polypeptide (VIP) + Phentolamine CG: placebo IG a & b: Dose: 25 μg VIP + a=1 mg, or b=2 mg (35 ml volume) Duration: 6 mo Frequency: max 3 times/ wk Compliance: 88.2%; 68.2% (133/195) completed phase I; 94.7% (105/126) CG: Dose: placebo (35ml volume) Duration: as IG Frequency: as IG Compliance: as IG Run In period: NR Wash out period: 36 hrs between injections F/u duration: NR | Primary outcome results: Duration of erection, median, IGa vs. IGb vs. CG: Phase I (n=132): 50 vs. 30 vs. 15 min Phase II (n=126): 60 vs. 40 vs.27.5 min Grade III erection, IG (a or b) vs. CG (a or b) (%): Phase I, a=72.2 vs. 13.1; b= 65.3 vs. 15.9; overall IG vs. CG=73.7 vs. 12.9 Phase II, a=75 vs. 12.6; b= 75 vs. 10.6; overall IG vs. CG= 69.1 vs. 13.7 Other outcomes assessed: OS: Satisfied or very satisfied: 80% of pts; quality of life improvement: 81% of pts and 76% or partners Withdrawals/drop-outs/loss to f/u: 107 (44.5%): n=45 (18.8%) no injection, n=62 post 1^st^ injection (AE, non compliance, other) WDAE: n=2 (death & priapism) TAE (n): a vs. b vs. placebo: % of injections with one or more AE: 47.5 vs. 45.4 vs. 68; bruising+ bleeding, 8 vs. 6 vs. 7; priapism (n=1) 0.05 vs. 0 vs. 0 [underlined: Overall incidence of urethral bleeding 0.9% for both phases] SAE: death n=1 (also n=1 MI) Ascertainment of outcomes assessed: Home filled diaries, f/u questionnaire
Schramek (1994) ^188^ Funding source: NR | N screened = NR N randomized = 24 (2 crossover design studies) Study I IG1, n = 7 (cross over a and b) Study II IG2, n = 17 (interventions a & b in random order) CG randomized = NA ITT analysis used for primary outcome: NR Inclusion: ED with hx of PgE_1_-induced penile pain Exclusion: NR Results reported for all pts (n=24) or by interventions (IG1 + IG2 (a), vs. IG1 + IG2 (b) | Age, median (range): 48, (28–62) y Co-morbidities: NR Previous ED treatment: PgE_1_ in all cases Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: 3 Physiologic ED: 21 (arteriogenic, neurogenic, caverno-venogenic) Mixed ED: 0 | IG1 & 2: a PgE_1_ b PgE_1_ + procaine IC IG1/IG2 (a) Dose: 20 μg Duration: NR Frequency: 1 dose IG1/IG2 (b): Dose: 20 μg PgE_1_ + 10 mg (IG1b), or 20 mg (IG2b) procaine Duration: NR Frequency all grps: 1 dose of each a and b Compliance all grps: 100% Run In period: NR Wash out period: ≥ 2 days F/u duration: 2 in 2 d intervals Other: Authors combined results from 2 studies | Primary outcome results: Full erection (grade 5), proportion of pts: IGa: 16/24 vs. IG1b 5/7 vs. IG2b 11/17 ▾ by 1 grade in n=7 (all improved to grade 5 after cross over tx): IG1: 2/7; IG2: 5/17 ▴ in grade: IG1 0/7 vs. IG1/17 Duration of erection IGa vs. IG1b vs. IG2b, median (range): 142 (20–360) vs. 122 (20–180) vs. 111 (15–360) min Time from injection to erection: NR Other outcomes assessed: BP, pulse rate, penile sensitivity Withdrawals/drop-outs/loss to f/u: 0 WDAE 0 TAE, n (%)of pts/grp: 37; IG1a vs. IG1b vs. IG2b: no pain 4 vs. 2 vs. 7; moderate pain 9 vs. 5 vs. 6; severe 2 vs. 0 vs. 4 Priapism: 2 events in n=1 after a and b SAE: 0 Ascertainment of outcomes assessed: Clinical evaluation of degree of erection on 5-point scale (1= no erection &5 = full erection)
Seyam (2005) ^189^ Funding source: NR | N screened = NR N randomized = 180 (crossover) IG1-9 n = 20 (in each grp) CG, n = 180 ITT analysis used for primary outcome: No Inclusion: ED ≥ 6 mo in duration Exclusion: Hx of priapism, sickle cell anemia, previous surgical intervention for ED | Age, mean (sd): 50.5 (11.7) yrs Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: IIEF-5 for 158 pts (Mean degree of ED = 7.6, sd = 5.8) Complete ED in 36; weak erection in 137; difficulty to maintain erection 6; recreational drug users = 12 (6.7%) | Concomitant medications: NR Duration of ED, mean: 40.2 mo Underlying disease, n (%): Organic disease 137 (76.5) 20 (11.2) arterial disease 6 (3.4) pure venous leakage Psychogenic ED, n (%): 16 (8.9) Physiologic ED, n (%): 163 Mixed ED: 67 (37.4) Other: NR | IG: PgE1, papaverine, phentolamine [trimix] CG: PgE1 IG1-3: Dose: 2.5 μg PgE1 + 5, 10 (IG2), 20 (IG3), mg Papaverine + 1 mg Phentolamine IG4–6: Dose: 5 μgs PgE1 + 5, or 10 (IG5), or 20 (IG6) mg Papaverine + 1 mg Phentolamine IG7–9: Dose: 10 μg PgE1 + 5, or 10 (IG8), or 20 (IG9) mg Papaverine + 1 mg Phentolamine CG: Dose: 20 μgs PgE1 Duration, all grps: approx 6hrs Frequency all grps: once Compliance all grps: 100% Run In period: NR Wash out period: 1 wk F/u duration NR | Primary outcome results:(IG vs. CG) Grade 4 + 5 erections, n (%): 122 (68) vs. 120 (67) Grade 5 erections, n (%): 61 (34) vs. 66 (37): Overall Cavernous artery diameter mean (sd), mm: IG: Right: 0.9(.21); Left: 0.9 (.2) vs. CG Right: 0.9 (0.2); Left: 0.9 (0.2), NS Peak systolic velocity, cm/s: IG Right: 29 (12); Left: 29 (12) vs. CG- Right: 30 (12); Left: 27 (12), NS Duration of erection, min: 120 (91) vs. 93 (67), NS Satisfaction, %: 63 (28) vs. 64 (26), NS Other outcomes assessed: Cost assessment, patient preference Withdrawals/drop-outs/loss to f/u: n =0 WDAE: n=1 (IG9) TAE: NR [AE: Priapism n=10 (none in IG2, IG4, and IG8); pain IG 32 (18%) vs. CG 26 (15%)] SAE: 0 Ascertainment of outcomes assessed: IEEF-5, Ultrasound imaging
Soderdahl (1997) ^190^ Funding source: NR | N screened = NR N randomized = 50 (cross over design) IG1, n = 27 (pts were cross over to other arm post wash-out) IG2 n = 23 (pts were cross over to other arm post wash-out) CG, n = NA ITT analysis used for primary outcome: NR Inclusion: men with untreated organic impotence, & a stable sexual partnership Exclusion: pts with hormonal therapy (low testosterone treatment); psychogenic impotence; stated preference for either of the treatments, pts not achieving erection after either of the treatment regiments were excluded from analysis | Age, mean (range): 62.3 (38–84) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED (yr): 40 (6–120) mo Underlying disease: Vascular n=15; surgical n=13; diabetic n=9; unknown n=7 Psychogenic ED: 0% Physiologic ED: All organic pts Mixed ED: NA | IG1: Trimix IG2: vacuum device CG: NA IG1: Dose: 0.25 –0.6 mL [30 mg/mL papaverine HCI, 5 mg/ mL phentolamine, 0.5 mg/ mL PGE) for at least 15 doses Duration: 18–20 mo Frequency: mean 5.8 uses /mo Compliance: 71% IG2: Dose: NA Duration: 18–20 mo Frequency: at least15 times; mean 5.4 use / mo Compliance: 80% Run In period: NR Wash out period: NR F/u duration: 18–20 mo | Primary outcome results: Satisfaction scores rated 0–10, IG1 vs. IG2, mean: Erection quality 5 vs. 4 (mean pre-treatment/ pre-impotence score = 1.6/ 6.6 for all) Penile sensation: 5 vs. 5 (pre impotence mean score = 6.5) Other outcomes assessed: partner reported quality & satisfaction Withdrawals/drop outs/loss to f/u: n=6 (12%) WDAE: NR TAE: NR [AE: n=11 bruising, injury or skin changes causing to stop treatment or drop out, IG1 n=4 (9%), vs. IG2 n=7 (16%)] SAE: required an extra visit to doctor IG1 n=5 (11%), IG2 n=2 (4.5%) Ascertainment of outcomes assessed: Pt filled questionnaire at end of 1^st^ period; clinician filled questionnaire at end of study
Sogari (1997) ^191^ Funding source: NR | N screened = NR N randomized = 230 IG1 n = 115 IG2 n = 115 CG n = NA ITT analysis used for primary outcome: NR Inclusion: ED Exclusion: NR Data reported as IG1 vs. IG2 | Age: NR Co-morbidities: NR Previous ED treatment: NR Smoking status: 50 (43.9%) vs. 38 (33.3%) Body weight: NR | Concomitant medications: NR Duration of ED, mean (sd): IG1: 32.2 (40.2) vs. 33.5 (54.8) mo Underlying disease (diagnosis): Hypertension; alcoholism; diabetes; Peyronie's disease; acute MI, or angina, all non sign. between grps | IG1: Trimix + atropine sulfate in combination (IC) IG2: Trimix alone IG1: Dose: 50 mg papaverine, 10 μg PgE_1_, 0.2 mg phentolamine (trimix), 0.075 atropine Duration: NA Frequency: 1 dose Compliance: NR IG2: Dose: Trimix as IG1 Duration: NA Frequency: 1 dose Compliance: NR Run In period: NR Wash out period: NR F/u duration: NR | Primary outcome results: erectile response assessed subjectively by examiner, IG1 vs. IG2: Tumescence 40 (35%) vs. 45 (40%) Poor erection 22 (19%) vs. 17 (15%) Full erection 52 (46%) vs. 52 (46%) Other outcomes assessed: intracorporeal pressure Withdrawals/drop-outs/loss to f/u: n=2; one from each grp WDAE: 0 TAE: (NR) AE: Painful sensation: 57 (50%), vs. 63 (53.8%)NR SEA: 0 Ascertainment of outcomes assessed: NA
Titta (2006) ^192^ Funding source: NR | N screened = NR N randomized = 57 IG1, n = 29 IG2, n = 28 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: men with non-nerve sparing (NNS) radical pelvic surgery screened one d prior to surgery; in a stable heterosexual relationship for at least 6 mo Exclusion: NR | Age, mean (range): 63.5 (55–72) y Race: NR Co-morbidities, n (%): NR Previous ED treatment: Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NA Underlying disease, n (%): clinically localized prostate cancer 50 (87.7); invasive bladder cancer 7 (12.3) Psychogenic ED, n (%): NR Physiologic ED, n (%): 57 (100) Mixed ED, n (%): NR | IG1: PgE1-IC + sexual counseling IG2: PgE1 alone IG1: Dose: 10μg (lowest efficious dose= 18.1μg, mean 9.1 μg) Duration: 18 mo Frequency: twice/wk Compliance: 72.4% IG2: Dose: as IG1(lowest efficious dose= 19.5μg, mean 13.8 μg) Duration: as IG1 Frequency: as IG1 Compliance: 28.5% Run In period: NA Wash out period: NR F/u duration: 18 mo (3, 6, 9, 12, and 18 mo) Note: open label sildenafil 100 mg (1 hr prior to sexual intercourse, min 4 doses/3 mo); all responders switched to sildenafil twice/wk at the end of trial | Primary outcome results: IIEF, mean score at 18 mo (IG1 vs. IG2): 26.5 vs. 24.3, p<0.05 IIIEF, mean pre vs. post surgery: 26.3 vs. 8.4 18 mo, IG1 vs. IG2: 26.5 vs. 24.3 Sexual satisfaction: pre vs. post surgery: 10.2 vs. 3 18 mo, IG1 vs. IG2: 9.7 vs. 6.8 IIEF-OF”: Pre vs. post surgery: 9.8 vs. 3.3 18 mo, IG1 vs. IG2: 9.2 vs. 7.8 IIEF-SD: Pre vs. post surgery: 8.6 vs. 8.5 18 mo, IG1 vs. IG2: 9 vs. 6.2 IIEF-SD: Pre vs. post surgery: 9.1 vs. 6.8 18 mo, IG1 vs. IG2: 9.0 vs. 7.3 Sildenafil responder rate, n (%): 8 (27.5) vs. 5 (17.8) Other outcomes assessed: Withdrawals/drop-outs/loss to f/u, n (%): 0 vs. 8 (28.5), p<0.05 WDAE, n (%): prolonged post injection pain 0 vs. 3 (10.7) TAE, n (%): NR SAE, n (%): NR Ascertainment of outcomes assessed: IIEF, and IC training test
Van der Windt, F (2002) ^193^ Funding source: Byk BV | N screened = NR N randomized = 70 (parallel) IG1, n = 35 IG2, n = 35 CG: NA ITT analysis used for primary outcome: No Inclusion: age range 20–70 yrs, medically & psychologically fit to use IC injection, in a stable & monogamous sexual relationship Exclusion: major organic cause for ED | Age, mean (range) 56 (23–75) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: premature ejaculation 20 patients (35%) | Concomitant medications: NR Duration of ED: mean= 3.4 y Underlying disease: NR Psychogenic ED (n): 12 vs. 13 Physiologic ED: 5 vs. 3 Mixed ED: 11 vs. 13 | IG1: papaverine-phentolamine (Androskat) + sexula counseling IG2: papaverine + phentolamine IG1: Dose: mean 0.34 ml (titrated from 0.25 ml) Duration: NR Frequency: NR Compliance: 10 (29%) IG2: Dose: mean dose = .27ml Duration: NR Frequency: Compliance: 7 (20%) Run In period: NR Wash out period: NR F/u duration, mean (range): 11.3 (2–19) mo Other: Screening determined dosage with use of hx, visual sexual stimulation and vibro-tactile stimulation | Primary outcome results: IG1 vs. IG2: Increase in penile circumference: mean (millimetres): 27 vs. 30 Duration of erection: mean: 47 vs. 56 min % (self reported) erection score: mean %: 84% vs.79% Other outcomes assessed: Acceptance of IC injection (mo used before stopping): 4.7 vs. 1.7 Withdrawals/drop-outs/loss to f/u: N= 13 WDAE: 12% discontinued due to prolonged erection TAE: NR AE in 14% of patients; 3 (5%) priapism, 4 (7%) haematoma, and 1 (2%) curvature of the penis SAE: 0 Aascertainment of outcomes assessed: Physical exam, telephone interview
Vanderschueren (1995) ^194^ Funding source: NR | N screened = NR N randomized = 210 (cross over) IG1-3 & CG, n = 210 (NR for dose allocations) ITT analysis used for primary outcome: NR Inclusion: men with ED, at least 4 mo in duration, with stable responders to PG-E1 (ED defined as inability to achieve rigidity sufficient for vaginal penetration) Exclusion: cavernous fibrosis, anatomical deformation of the penis, Peyronie's disease r a hx of priapism, major disease, drugs that could substantially affect the evaluation of EF | Age, mean (range): 53 (29–70) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 4.8 (0.5–41) y Underlying disease: diabetes in 7%; other NR Psychogenic ED: 36% Physiologic ED: 28%; (vasculogenic 21%, diabetes I 7%) Mixed ED: 15% | IG1: PgE1 new sterile solution IG2: PgE1 sterile powder IG3: PgE1 pediatri sterile solution Each administered in 4 doses) CG: placebo IG1-3: Dose: a= 2.5, or b=5, or c=10, or d=20 μg Duration: NR Frequency: one injection of each formulation at the randomized dose Compliance: NR CG: Dose: 0 μg PgE1 Duration: NR Frequency: as IG Compliance: NR Run In period: NR Wash out period: at least 3 d F/u duration: NR | Primary outcome results: Duration of erection, mean (sd): [IG1 vs. IG2 vs. IG3], min: 2.5 μg: 30 (9) vs. 27 (8) vs. 33 (8) 5 μg: 52 (10) vs. 68 (12) vs. 64 (12) 10 μg c: 29 (8) vs. 35 (9) vs. 35 (9) 20 μg: 52 (11) vs. 50 (10) vs. 51 (11) CG: 0 (0) vs. 0.5 (0.5) vs. 1.6 (1.4) % of pts with positive response, RigiScan (>/=70% for >/= 10 min), and clinical assessment, data extracted from bar graph and it is approximate: 2.5 μg: RigiScan: 33 s. 27 vs. 40; clinical assessment: 40 vs. 33 vs. 44 5 μg: RigiScan 50 vs. 48 vs. 52; clinical assessment: 65 vs. 75 vs. 70 10 μg: RigiScan 38 vs. 48 vs. 39, clinical assessment 50 vs. 52 vs. 63 20 μg: RigiScan 43 vs. 45 vs. 42; clinical assessment 55 vs. 58 vs. 55 CG: RigiScan 0 vs. 2 vs. 5; clinical assessment 0 vs. 0 vs. 5 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 3 (1.5%) WDAE: n=3; severe penile pain 1 (0.5%); systemic medical events 2 (1%) TAE: NR; AE: penile pain, IG1 9% vs. IG2 14% vs. IG3 17% vs. CG 11% SAE: 0 Ascertainment of outcomes assessed: RigiScan; clinical assessment
Viswaroop (2005) ^195^ Funding source: NR | N screened = N randomized = 50 IG1, n = 25 IG2, n = 25 CG, n = NA ITT analysis used for primary outcome: NR Inclusion: men 21–65 y wit ED (irrespective of aetiology, marital status and duration of ED) Exclusion: contraindication to use of sildenafil or papaverine | Age, mean (sd): 30 (10.2) Race: NR Co-morbidities, n (%): DM 6 (12); hypertension 3 (6); abused alcoholic 2 (4); depressive illness 4 (8) Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): NR Psychogenic ED, n (%): 30 (60) Physiologic ED, n (%): 20 (40) Mixed ED, n (%): NR | IG1: papaverine IC then oral sildenafil IG2: oral sildenafil then papaverine IC injection IG1: Dose: papaverine 30 mg; sildenafil 50 mg Duration: NA Frequency: sinlgle dose Compliance: NR IG2: Dose: as IG1 Duration: as IG1 Frequency: as IG1 Compliance: NR Run In period: Wash out period: 2 d between tx for each arm F/u duration: 5 min post injection of papaverine; 30 min post ingestion of sildenafil | Primary outcome results: Penile length (cm), mean (sd): baseline 7.71 (1.26) papaverine: 11.98 (2.4) sildenafil 11.66 (2.20) Penile circumference (cm), mean (sd): Baseline: 7.50 (1.07) Papaverine: 10.2 (1.5) Sildenafil: 9.67 (1.39) Other outcomes assessed: angle of erection; Pts tx preference Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): NR TAE: NR; AE reported, priapism n=5 (10) with injection; headache 2(4), blurring vision 1 (2) and dyspepsia 1 (2) SAE, n (%): 0 Ascertainment of outcomes assessed: Penile measurement; interview
von Heyden (1993) ^196^ Funding source: Deutsche Forschungsge-meinschaft | N screened = NR N randomized = 16 IG/ CG, n = 16 (crossover design) ITT analysis used for primary outcome: NR Inclusion: undergoing home auto-injection with PgE_1_ Exclusion: ED due to severe venous incompetence, sickle cell anemia, or endocrinological, neurological or psychiatric dx; Peyronie's dx; hx of priapism, coagulopathy, recent MI, unstable angina or stroke; use of medication known to interfere with EF within 1 mo of study entry | Age, mean (sd): 56, range 46–70 y Co-morbidities: DM 2, heart attack 2, coronary bypass 2, hypertension 1, transurethral prostatic resection 1 Previous ED treatment: PgE_1_ for mean of 1.3 yr (range 0.3–6); mean dosage 6.21 μg (95% confidence interval 4.33–8.10) Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: arterial insufficiency 9, moderate venous insufficiency 1, mixed vascular disease 6 Psychogenic ED: 0 Physiologic ED: 16 Mixed ED: 0 Other: 1 patient had borderline hypergonadotropic hypogonadism | IG: PgE_1_ CG: placebo IG: Dose: mean effective dose 21.4 (2.5 –40) μg Duration: NR Frequency: varied (injections were repeated until erection lasted longer than 2 hr, or drug intolerance developed with minimum of 2 d between injections) Compliance: CG: Dose: placebo (saline) Duration: NR Frequency: Placebo was given at random during the escalating dose schedule Compliance: Run In period: NR Wash out period: 2 or more d F/u duration: 2 hrs post injection | Primary outcomes: Approximate % of patients with highest value at or below dosage IG [2.5–40 μg (range)] vs. CG Maximal rigidity base: 19–98% vs. 0% Maximal rigidity tip: 19–98% vs. 7% Maximal sustained rigidity base: 19–98% vs. 0% Maximal sustained rigidity tip: 12–98% vs. 0% Total duration of ≥ 60% rigidity base 22–100% vs. 0% Total duration of ≥ 60% rigidity tip 41–100% vs. 8% Other outcomes assessed: Rigidity assessed with penis buckling test; cavernous artery peak flow velocity; systolic & diastolic BP Withdrawals/drop-outs/loss to f/u: 4 WDAE: 4 (pain on last dose (15 μg in 2; 20 μg, and 25 μg in 2) TAE: 22/135 injections (16.3%); all: Burning sensation or mild to moderate penile pain 18/135 IG (13.3%) Haematoma 2/135 IG (1.5%) SAE: 0 Ascertainment of outcomes assessed: RigiScan™ Rigidity Assessment System
Wegner (1994) ^197^ Funding source: | N screened =60 N randomized = 20 (crossover trial) IG1/ IG2 (a,b), n =20 ITT analysis used for primary outcome: NR Inclusion: Men with ED who presented to ED clinic for evaluation. Who undergo evaluation of the cause of their dysfunction, including sexual hx, physical exam. Exclusion: NR | Age, mean (range): 54.2 (29–87) y Co-morbidities: NR Previous ED treatment: NR Smoking status, n (%): (30) Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: n (%); DM 4 (20) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: n (%); Alcohol abuse 2 (10) Primary neurologic causes 1 (5) | IG1: PgE1 IG2 (a,b): SIN-1 IG1: Dose: 20 μg Duration: NR Frequency: once min 3 days inbetween Compliance (%): 100% IG2a: Dose: 1 mg Duration: NR Frequency: once Compliance: 100% IG2b: Dose: 2 mg Duration: Frequency: once Compliance: 100% Run In period: NR Wash out period: 3 d between injections F/u duration(on and off treatment): NR | Primary outcome results: IG1vs. IG2 a vs. IG2 b Erectile Response, n (%): Full rigidity (5): 2 (10) vs. 0, vs.0 Full medium rigidity (4): 4 (20) vs. 2 (10) vs. 2 (10) Minimal to Full without rigidity (1–3): 14(70) vs. 18 (90), vs. 18 (90) No response: 0 in all grps Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: No dropouts WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: Clinician assessed quality of erection using a 6 point scale, (0–5, with 0 being no response, 4 Full medium rigidity. and 5 Full rigidity)
Wegner (1995) ^198^ Funding source: NR | N screened =60 N randomized =40 (cross over) IG1-3, n= 40 ITT analysis used for primary outcome? NR Inclusion: Pts with ED => 6 mo duration Exclusion: NR | Age, mean (range): 53 (34–71) yr Co-morbidities: NR (see ‘Other’) Previous ED treatment: NR Smoking status: n=12 Body weight: NR Other: alcohol abuse (n=3), DM (n=8) | Concomitant medications: NR Duration of ED: 3.2 y (6 mo – 7 y) Underlying disease: pelvic surgery (n=3), neurological causes (n=2) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: Diagnosis of ED included testing with PGE1, cause of ED, sexual hx, physical examination | IG1: Pg-E1 IG2: linsidomine chlorhydrate (SIN-1) IG3: SIN-1 + urapidil IG1: Pg-E1 Dose: 20 μg Duration: NR Frequency: once IG2: SIN-1 Dose: 1 mg Duration: NR Frequency: once IG3: SIN-1 + urapidil Dose: 1 mg (SIN-1), 10 mg (urapidil) Duration: NR Frequency: once Compliance all: NR Run In period: NR Wash out period: 3 d F/u duration: 3 d (assessed 5, 10, 20, 30 min after injection) | Primary outcome results: N pts with full response (grade 6) (rigidity)/ rigid erection (grade 5), n (%) IG1: 8 (20)/ 8 (20) IG2: 0 (0)/ 3 (8) IG3: 2 (5)/ 8 (20) IG1 vs. IG2, p = 0.0001 IG2 vs. IG3, p = 0.0004 Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE: NR AE, n of events: 5 severe hypotension in IG3; pain upon injection IG1=3; IG2=1; IG3=3 SAE: NR Ascertainment of outcomes assessed: inspection and palpation (0= no response; 5= full tumescence; 6= full tumescence with rigidity)

List of abbreviations: %=percent, ▴=increased, ▾=decreased, AE=adverse event, SAE=serious adverse event, BMI=body mass index, CC=controlled clinical trials, CG=comparator/control group, ctrls=controls, DM=diabetes mellitus, E_1_ IC=intracavernosal injection, ECG=electrocardiograms, ED=erectile dysfunction, EDV=end-diastolic velocity, f/u=follow-up, FMD=flow mediated dilation, GAQ=global assessment question, GEQ=global efficacy question, grp=group/s, HbA1C=haemoglobin, hr=hour(s), hx=history, IG=intervention group, IIEF= international index of erectile function (EF=erectile function, OF=orgasmic function, OS=overall satisfaction, SD=sexual desire), ITT=intent-to-treat (Y = yes, N = no, NR = not reported), IU=intraurethral, kg=kilograms, lbs=pounds, LUTS=lower urinary tract symptoms, M=male, max=maximum, mo=month(s), NA=not applicable, PADAM=partial androgen deficiency of the aging male, PgE_1_=Prostagladin, PRL=prolactin, PSA=prostate-specific antigen, RAU=rigidity activity unit, RCT=randomized control trial, SBP=systolic blood pressure, sign.=significant; TAE=total adverse events, TAU=tumescence activity unit, vs.=versus, WDAE=withdrawals resulting from adverse events, wk=week(s), yr=year(s).

Evidence Table C6. Subcutaneous Treatment Trials

Author Funding | N; study design; eligibility | Participants characteristics | Diagnosis details | Intervention | Outcomes
Rosen, RC (2004) ^199^ Funding source: NR | N screened = NR N randomized = 25 IG1/IG2/CG, n = 25 (3 way cross over) ITT analysis for primary outcomes: NR Inclusion: age 21–55 y; within 40% of ideal weight, ED diagnosis of 6 mo or longer; IIEF EF score 16 or less; inadequate response to 100 mg Viagra defined by ability to attain erection sufficient for intercourse equal or less than 50% of times within last 12 mo Exclusion: Current use of Viagra (last 4 wks prior to enrolment); ED due to untreated endocrine disease, penile anatomic deformities, prostate cancer or radical prostatectomy; clinically S hepatic, renal, cardiovascular, psychiatric or CNS disease, (i.e. stroke or SCI) | Age, mean (sd): 48 (5), range 37–54 y Race, n (%): White 19 (76), Black 5 (20), Hispanic 1 (4), other 0 Co-morbidities, n (%): DM 2 (8); hypertension 7 (29); hyperlipidemia 3 (12) Previous ED treatment: Viagra (100 mg) Smoking status: 11 (42%) Body weight, mean (sd): 97 (18) kg, range 64–129 kg | Concomitant medications: NR Duration of ED, mean (sd): 8 (5) y, range 2–22 y Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: subcutaneous PT-141 low dose (+ visual sexual stimulation) IG2: subcutaneous PT-141 high dose (+ visual sexual stimulation) CG: placebo IG1/IG2: Dose: 0.4 mg (IG1), 0.6 mg (IG2) injected in the lower right quadrant of abdomen (3 way crossover design always starting with lower dose) Duration: NA Frequency: once/ dose, three visits Compliance: 100% CG: Dose: NA Duration: NA Frequency: as IG Compliance: 100 Run In period: NA Wash out period: 3–14 d F/u duration: last outcome measure taken up to 145 min post injection (pts were monitored for 12 & 24 hr post injection) | Primary outcomes (EF): IG1 (n=24) vs. IG2 (n=21) vs. CG (n=23), mean (SE): Duration of rigidity, min: >/= 60%, base: 28 (6), vs. 41 (8), vs. 6. (2)/; tip: 19 (5) vs. 24 (6), vs. 4 (2) >/= 80% base: 14 (4), vs. 17 (5), vs. 2 (0.6)/; tip: 5 (2), vs. 8.(3), vs. 0.4 (0.2) RAU: Base: 29 (5), vs. 41 (6), vs. 9 (2) Tip: 23 (4), vs. 33 (5), vs. 7 (2) Other outcomes assessed: Tumescence activity untis (TAU) Withdrawals/drop-outs/loss to f/u: n=1 (this pts was replaced) WDAE: n=0 TAE: 24 vs. 24 vs. 0; including nausea, headache, vomiting, back pain, diaphoresis, flushing, fatigue, muscle cramps SAE: 0 Ascertainment of outcomes assessed: RigiScan TM; Rigidity Assessment System (Pharmacokinetic data, 3) Other: pts with severe ED (IIEF- EF score 6–10) (n=10): 6 mg PT-141 resulted in mean duration of >/= 60 and >/=80% base rigidity of 36 and 15 min (p<0.01) respectively compared to 8 and 2 min after placebo
Segraves (1991) ^200^ Funding source: NR | N screened = NR N randomized = 12 IG/7 CG, n = 12 ITT analysis used for primary outcome: NR Inclusion: coital erectile failure for at least 6 mo, and any 1 or more of hx of adequate erections upon awakening at least 2/wk for preceding mo, hx of adequate erections lasting ≥ 5 min during foreplay and/or hx of adequate EF during masturbation Exclusion: current use of hypotensive or psychoactive medication; prior use of neuroleptic medications; penile blood pressure index ≤ 0.70; serum testosterone ≤ 450 ng/mL; serum PRL ≥ 30 ng/mL; erectile problem judged to be related to current marital discord; presence of dx known to be frequently associated with ED | Age: NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: 12 Physiologic ED: 0 Mixed ED: 0 | IG: apomorphine hydrochloride subcutaneously (brachial) CG: placebo subcutaneously (brachial) IG1: Dose: (titrated wkly until full rigidity or AE) 0.25, and 0.50 0.75 and 1.0 mg n=12 received only first 2 doses; n=9 first 3 doses, and n=5 all doses Duration: NR Frequency: once/wk Compliance: NR CG: Dose: placebo Duration: NR Frequency: once /wk Compliance: NR Run In period: NR Wash out period: 50 min between injections in each session; 1 wk between sessions F/u duration: NR | Primary outcome results: penile tumescence (▴ in circumference): n=11 exceeded 1 cm after apomorphine injection Average max erection = 2 cm, range 0.3–3.0 cm Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: NR; AE, n (%): 8 (67); yawning, drowsiness, nausea, and extreme SAE: NR Ascertainment of outcomes assessed: Barlow strain gauges; Max erection, made by visual inspection without palpation, rated independently by subject and investigator on scale of 0–100%; Max level of SD rated on scale of 0–100% by subject Other: 3 pts (25%) did not proceed to the next dose level due to AE; sign. relationship between nicotine use an absence of AE (chi-square 6.9, p<0.01)
Wessells (2000) ^201^ Companion study (part II) ^202^ Study I (psychogenic study) Funding source: | N screened = NR N randomized = 10 (cross over) IG/ CG = 10 ITT analysis used for primary outcome: NR Inclusion: age 18–75 y, part I: psychogenic ED pts with normal organic etiology & normal nocturnal penile tumescence (> 10 in of tip rigidity > 70%); part II, men with organic ED (mean organic risk factor of 2.2) (ED defined as the persistent inability to obtain and maintain erection sufficient for sexual satisfaction) Exclusion: Concurrent use of erectogenic medications, radical prostatectomy, cancer-chemotherapy, Peyronie's disease, or other genital anomalies | Age, mean (range): Reported for study I + Study II: 51.6 (22–67) y Race (%): NR Co-morbidities: NR Previous ED treatment, n: IC injection; sildenafil 5; IU Pg E- IU 1 Smoking status: smokers n=2 Body weight: NR Other: mean serum testosterone level: 362 mg/ml; mean IIEF score (items 3 and 4) 0.77 (0–2) | Concomitant medications: testosterone replacement therapy (n=3) Duration of ED: NR Underlying disease, n: reported for total pts, hypoganodism 3; hypercholesterolemia 5; obesity 4; hypertension 3; peripheral neuropathic injury 2; DM 2; heart dx 2; venoocclusive dysfunction 1; pudendal arterial insufficiency 1 Psychogenic ED: 100% Physiologic ED: 0 Mixed ED: 0 Other: NPT (mean baseline): 3 erectile events /night, 30 min of base rigidity > 60%, 9 min tip rigidity > 80% | IG: subcutaneous injection Melanotan II CG: placebo IG1: Dose: 0.025–0.157 mg/kg (total injections, part I & II = 39) Duration: NR Frequency: 2 injections Compliance: 100% CG: Dose: placebo (total injections study I & II Duration: NR Frequency: as IG Compliance: 100% Run In period: NR Wash out period: 48 hrs F/u duration: 6 hrs post injection Other: one subject (no allocation to study grps) received three placebo and one active injections erroneously | Primary outcome results: Erectile activity/injection: NR (combined results of Study I & study II 27/39 (69%) vs. 1/41 (2.4%) RigiScan (mean), n=16 injections: Erections with response (%): 75 vs.0 Erectile events (n): 3.45 vs. 2.35 Total erectile duration (min): 163 vs. 55 Tip rigidity 80–100% (min): 38 vs. 3 Tip rigidity 60–79% (min): 40 vs. 5 Average tip rigidity (%): NR Erectile latency (min): 127 vs. ND Tip RAU: 78 vs. 10 Tip TAU: 50 vs. 14 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: NR WDAE: 0 TAE: combined results for Study I & II; n of events/total injections, (%) Nausea: 15/39 (38) vs. 4/41 (10) Stretch/yawn: 22/39 (56) vs. 5/41 (12) SAE: 0 Ascertainment of outcomes assessed: Penile rigidity by RigiScan and visual analog scale; SD and side effects by questionnaire
Wessells, (2000) ^201^ Companion study (part II) ^202^ Study II (organic study) Funding source: | N screened = NR N randomized = 10 (cross over) IG/ CG = 10 Inclusion: age 18–75 y, men with organic ED (mean organic risk factor of 2.2) (ED defined as the persistent inability to obtain and maintain erection sufficient for sexual satisfaction) Exclusion: Concurrent use of erectogenic medications, radical prostatectomy, cancer-chemotherapy, Peyronie's disease, or other genital anomalies | Age, mean (range): Part II 56.2 (37–67) y Co-morbidities: NR Previous ED treatment, n: intracavernous injection; sildenafil 5; IU Pg E- IU 1 Smoking status: smokers n=2 Body weight: NR Other: mean serum testosterone level: 362 mg/ml; mean IIEF score (items 3 and 4) 0.77 (0–2) | Concomitant medications: testosterone replacement therapy (n=3) Duration of ED: NR Underlying disease, n: as study I Psychogenic ED: 0 Physiologic ED: 100% Mixed ED: 0 Other: see study I | IG: subcutaneous injection Melanotan II CG: placebo IG1: Dose: 0.025–0.157 mg/kg Duration: NR Frequency: two injections; total injections = 19 Compliance: 100% CG: Dose: placebo Duration: NR Frequency: as IG Compliance: 100% Run In period: NR Wash out period: 48 hrs F/u duration: 6 hrs post injection Other: * n=1 received three placebo and only one Melanotan II injections erroneously | Primary outcome results: Erectile activity/injection: NR (combined results of Study I & study II 27/39 (69%) vs. 1/41 (2.4%) RigiScan (mean): Erections with response (%): 63 vs. 5 Erectile events (n): 3 vs. 0.7 Total erectile duration (min): 98 vs. 25 Tip rigidity 80–100% (min): 45 vs. 2 Tip rigidity 60–79% (min): 10 vs. 1 Average tip rigidity (%): 47 vs. 6 Erectile latency (min): 8 vs. ND Tip RAU: 59 vs. 5 Tip TAU: 29 vs. 6 IIEF- Q12 (sd), [IG (19 injections) vs. CG (21 injections)] very low or none 6 vs. 1 Low 3 vs. 3, Moderate 5 vs. 1, High 5 vs. 0, Very high 0 vs. 0 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: NR WDAE: 0 TAE: combined results for Study I & II; n of events/total injections, (%) Nausea: 15/39 (38) vs. 4/41 (10) Stretch/yawn: 22/39 (56) vs. 5/41 (12) SAE: 0 Ascertainment of outcomes assessed: Penile rigidity by RigiScan and visual analog scale; SD and side effects by questionnaire

List of abbreviations: %=percent, ▴=increased, ▾=decreased, AE=adverse event, SAE=serious adverse event, BMI=body mass index, CC=controlled clinical trials, CG=comparator/control group, ctrls=controls, DM=diabetes mellitus, E_1_ IC=intracavernosal injection, ECG=electrocardiograms, ED=erectile dysfunction, EDV=end-diastolic velocity, f/u=follow-up, FMD=flow mediated dilation, GAQ=global assessment question, GEQ=global efficacy question, grp=group/s, HbA1C=haemoglobin, hr=hour(s), hx=history, IG=intervention group, IIEF= international index of erectile function (EF=erectile function, OF=orgasmic function, OS=overall satisfaction, SD=sexual desire), ITT=intent-to-treat (Y = yes, N = no, NR = not reported), IU=intraurethral, kg=kilograms, lbs=pounds, LUTS=lower urinary tract symptoms, M=male, max=maximum, mo=month(s), NA=not applicable, PADAM=partial androgen deficiency of the aging male, PgE_1_=Prostagladin, PRL=prolactin, PSA=prostate-specific antigen, RAU=rigidity activity unit, RCT=randomized control trial, SBP=systolic blood pressure, sign.=significant; TAE=total adverse events, TAU=tumescence activity unit, vs.=versus, WDAE=withdrawals resulting from adverse events, wk=week(s), yr=year(s).

Evidence Table C7. Intra-urethral Suppositories

Author Funding | N; study design; eligibility | Participants characteristics | Diagnosis details | Intervention | Outcomes
Ekman, P (2000) ^203^ Funding source: Astra Lakemedel AB | N screened = NR N randomized = 166 IG1, n = 83 IG2, n = 83 CG, n = NA Intention to Treat (ITT) analysis: yes Inclusion: men 18 y or older, with ED Exclusion: hypersensitivity to alprostadil (MUSE), abnormal penile anatomy, acute or chronic urethritis or indwelling catheter, penile implant, untreated hypogonadism, testosterone substitution for < 3 mo, known risk of priapism, concomitant tx with appetite suppressants or anticoagulants, partner planning to become or already pregnant. Also concomitant dx (poorly controlled diabetes, hypertension, unstable angina, heart failure, severe vascular dx, severe neurological or psychiatric dx) | Age, mean (sd): 60 (10) y Race: 100% Caucasian Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight, mean (sd): 86 (12) kg | Concomitant medications: NR Duration of ED: 41 (31) mo Underlying disease, (%): > 1 cause: Vascular 47 vs. 43 neurogenic 18 vs. 17 Diabetes 21 vs. 21 hormonal 0 vs. 4 Psychogenic 12 vs. 7 Unknown 27 vs. 27 Other 22 vs. 17 Psychogenic ED: NA Physiologic ED: NA Mixed ED: NA Other: capable of partial erection mean (%)= 78 (76 vs. 81) | IG1: PgE1 alprostadil (MUSE) (optional pubic band) IG2: PgE1 alprostadil (MUSE), (optional pubic band) IG1: Dose: starting dose of 250 μg (clinic), titrated up to 250,500,1000 μg or down to 125 μg after 4 wks at 4 wk intervals (home application) Duration: 12 wks Frequency: at least 4 applications/ 4 wk Compliance: NR IG2: Dose: as IG1, starting dose of 500 μg (titration regiment as IG1) Duration: 12 wks Frequency: as IG1 Run In period: NR Wash out period: NR F/u duration: NR | Primary outcomes (EF): Quality of erection reported for both IG1 & IG2 combined: Grade 4/5 at least once, n (%): 122 (73); these pts all reported coitus Grade below 4, n (%): 44 (27) IIEF (Q1–5 & 15), mean change in score (%): Q1= 1.8 (100); Q2= Q3=1.7 (100); Q4=1.9 (146); Q5=1.9 (136); Q15=1.2 (136) all sign. p <0.001 Final dose (% of total n=142): 125 μg - 1%; 250 μg - 6%; 500 μg - 18%; 1000 μg - 75% Sexual intercourse at least once: 113 (68%) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 24 (included 1 due to depression, and 3 unknown WDAE: 9 (5%) penile pain, hypotension) TAE: NR AE, n (%): Pain 50 (30%) with 4 (2%) rated severe; Hypotension, dizziness: (no detail reported) SAE: 0 Ascertainment of outcomes assessed: Pts filled personal diary; IIEF; Erection Assessment Scale (EAS)
Lazzeri (1994) ^204^ Funding source: NR | N screened = NR N randomized = 20 (parallel design) IG1, n = 5 IG2, n = 5 IG3, n = 5 CG, n = 5 ITT analysis used for primary outcome: NR Inclusion: ED Exclusion: NR | Age, mean (SE): 55.4 (5) y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: 20 Physiologic ED: 0 Mixed ED: 0 | IG1: capsaicin IU IG2: papaverine IC IG3: papaverine IC + capsaicin IU CG: placebo IU IG1: Dose: capsaicin 10^–5^ M Duration: NR (injection length= 2 min) Frequency: 1 dose IG2: Dose: 8 mg Duration: as IG1 Frequency: 1 dose IG3: Dose: 8 mg + capsaicin 10^–5^ M Duration: as IG1 Frequency: 1 dose CG: Dose: saline Duration: as IG1 Frequency: 1 dose Compliance all grps: NR Run In period: NR Wash out period: NA F/u duration: NR | Primary outcome results: No response was reported for all variables with placebo, results for IG1 vs. IG2 vs. IG3: Penile diameter, Mean (sd) maximal ▴: 2.9 (0.93) vs. 3.7 (1.1) vs. 3.8 (0.96) Rigidity, mean maximal (%): 43 (12) vs. 63 (10) vs. 74 (16) Mean latency (seconds) 219 (44) vs. 198 (10) vs. 107 (29) Mean duration (seconds) 322 (58) vs. 248 (39) vs. 390 (48) Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: NR SAE: NR Ascertainment of outcomes assessed: RigiScan™ Rigidity Assessment System
Padma-Nathan (1997) ^205^ Companions ^206^ – ^208^ Funding source: Vivus Inc. | N screened = NR N randomized, phase I- clinic test = 1511 (at clinic test with alprostadil) N randomized - Phase II-home tx= 996 (responders to alprostadil test) IG, n = 485 CG, n = 511 ITT analysis used for primary outcome: no Inclusion: men with chronic ED without spontaneous erection sufficient for intercourse within past 3 mo; response = 4 or 5 to initial dose response test (125 –1000 μg alprostadil) Exclusion: hx of urethral stricture or obstruction, indwelling urethral catheter, penile implant or prior penile surgery, sickle cell dx, paraplegia or quadriplegia, congestive heart failure, unstable angina, or recent acute MI; poorly controlled DM (complete list could be found in original study) | Age, mean (range): 62 (38–84) vs. 61 (30–83) y Co-morbidities: NR Previous ED treatment: 52% vs. 57% Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: 51 (3–528) mo Underlying disease: Vascular disease: 29% v. 28% Diabetes: 19 vs. 19 Surgery or trauma: 32% vs. 31% Other: 21% vs. 21% Psychogenic ED: NA Physiologic ED: 100% primary organic ED Mixed ED: NA Other: capable of partial erection (% of men): 63.3% vs. 60.9% | IG: alprostadil home tx CG: placebo home tx IG1: Dose: 125 μg (n=116, 12%), 250 μg (n=171, 17%), 500 μg (n=302, 30%), 1000 μg (n=407, 41%) Duration: 3 mo Frequency: NR Compliance: NR CG: Dose: same as IG Duration: 3 mo Frequency: NR Compliance: NR Run In period: NR Wash out period: NR F/u duration: 3 mo Other: 88% of IG rated the transurethral application of alprostadil as neutral | Primary outcome results: IG (n=411) vs. CG (n=500), % of successful tx Intercourse: 50 vs. 10 Intercourse/orgasm: 56 vs. 15 Intercourse/orgasm/10-min erection sufficient for intercourse: 57 vs. 15 Other outcomes assessed: 88% of IG rated the transurethral MUSE neutral, comfortable or very comfortable Withdrawals/drop-outs/loss to f/u: n=123 (12) WDAE, n (%): 15 (2) TAE, n (%): Penile pain: 159 (33) vs. 17 (3); also in 11% of administrations of alprostadil Minor urethral trauma: 25 (5) vs. 5 (1) Urinary tract infection: 1 (0.2) vs. 3 (0.6) Priapism-prolonged erection: 0 vs. 0 Penile fibrosis: 0 vs. 0 Dizziness: 9 (2) vs. 1 (0.2) Hypotension (dose response observed):0 v. 1 (0.2) SAE: NR Ascertainment of outcomes assessed: EAS (1= no response to 5= full rigidity); comfort by self assessment
Peterson (1998) ^209^ Funding source: VIVUS Inc. | N screened = NR N randomized = 234 (CCT- crossover design) IG1/IG2/IG3/ CG, n = 234 ITT analysis used for primary outcome: NR Inclusion: men with ED 3 mo before enrolment, in stable relationship, who tolerated, and had a measurable response to 500 μg alprostadil in clinic Exclusion: Waking or early-morning erections sufficient for vaginal penetration within past 3 mo; hx of urethral stricture or obstruction; penile implant; indwelling urethral catheter or penile surgery; sickle cell dx; paraplegia or quadriplegia; uncontrolled congestive heart failure; unstable angina or acute MI within in 3 mo; poorly controlled DM; use of investigational tx other than IC injections within 2 mo of study entry; hx of epilepsy; active vasculitis; life expectancy < 6 mo; morbid obesity | Age, mean SD): 60 (10), range 26.8–81.5 y Co-morbidities: NR Previous ED treatment, n (%): None 94 (40), counselling 22 (10), hormonal tx 44 (18.8), IC 78 (33), band therapy 10 (4), vacuum pump 43 (18), other 6 (3) Smoking status NR Body weight: NR Other: Acute onset 67 (29), gradual onset 167 (71) | Concomitant medications: Testosterone replacement therapy and concomitant medications for unrelated conditions continued at stable dose throughout study Duration of ED: 4, range 0.25–30 Underlying disease: Vascular 92 (39), diabetes 42 (18), surgery/trauma 58 (25), other 42 (18) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: MUSE IG2: prazosin hydrochloride IG3: MUSE+prazosin (ratios 1:1, 1:2 and 1:4) CG: placebo IG1: Dose: 125, 250, 500 or 1000 μg Duration: 2–4 wks Frequency: 2 doses IG2: Dose: 250, 500, 1000 or 2000 μg Duration: 2–4 wks Frequency: 2 doses IG3: Dose: 1 of 9 combinations Duration: 2–4 wks Frequency: 2 doses CG: Dose: placebo Duration: 2–4 wks Frequency: 1 dose Compliance all: NR Run In period: NA Wash out period: at least 2 wks F/u duration: 7, -60 min after dosing | Primary outcome (EF): Grade 3 or higher, (%): 52 vs. 13 vs. 59 vs. 3 Grade 4 or 5, (%): 31 vs. 3 vs. 36 vs. 0.4 Median visual analogue scale (1–100), range: 37–50 vs. 8–22 vs. 42–60 vs. 4 Other outcomes assessed: pts comfort with Withdrawals/drop-outs/loss to f/u: 17 WDAE: 2 TAE: NR AEs, % (range) of total doses: penile pain or discomfort: 17–24 vs.1–6 vs. 17–32 vs. 2 testicular pain: 2–4 vs. 0–1 vs. 2–7 vs. 0.4 urethral pain: 1–9 vs. 0–2 vs. 2–14 vs. 2 dizziness 0–6 vs.0–1 vs. 0–12 vs. 0; hypotension: 1–4 (dose response for MUSE)vs. 0–2 vs. 0–14% vs. 0 prolonged erections, 4–6 hr, n (%): 2 (1) minor urethral bleeding, n (%): 12 (5) SAE: 0 Ascertainment of outcomes assessed: erection grading system (0–5)
Shabsigh (2000) ^210^ Funding source: Schwarz Pharmaceuticals AL | N screened = NR N randomized = 111 (two phase cross over study, Phase I: office dose titration; phase II: at home treatment) IG1/IG2, n = 111 CG, n = NA ITT analysis used for primary outcome: yes (Phase I, n= 95; Phase II, n= 68) Inclusion: ED at least 6 mo, stable heterosexual relationship Exclusion: pts with past IC or IU tx, chemotherapy, other meds that might produce bleeding or bruising after drug administration, monoamine oxidase inhibitors up to 2 wk before enrolment, \concomitant medication for ED or oral alpha-adrenergic receptor blocking agents, had ED due to urologic abnormality, penile fibrosis or untreated endocrine disorder (hypogonadism) or systolic BP < 100 mm Hg | Age, mean (sd): 59.2 (10.6) y, range 30–79 y Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: Blood pressure, mean (sd): Systolic: 139(15) mm Hg Diastolic: 83 (8) mm Hg Heart rate: 73 (10) beats per minute | Concomitant medications: NR Duration of ED, mean (sd): 5 (4) y Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: IC injection of alprostadil (EDEX) IG2: IU injection of alprostadil (MUSE) with option of ACTIS IG1: Dose: mean optimal dose = 27.3 μg (up to 40 μg, also most frequently used dose) Duration: phase I=1–14 d; phase II=21 d Frequency: phase II=max of 9 IU/ 21 d administrations in 21 d Compliance: NR IG2: Dose: optimal dose = 921 μg (up to 1000 μg, 33% of all administrations) Duration: as IG1 Frequency: as IG1 Compliance: NR Run In period: 1 to 14 d Wash out period: NR F/u duration: 3 wk off treatment | Primary outcome results: IG1 vs. IG2 Grade ≥ 3, n (%): By physician: 59 (62) vs. 19 (20) Patient assessment: 63 (66) vs. 25 (26) Positive buckling tests (1 kg), n (%): 58 (61) vs. 20 (21) Erection sufficient for intercourse, (%): 82 vs. 47 Satisfaction rating mean: 6 vs. 3 IIEF score, baseline all vs. IG1 vs. IG2, mean (sd): EF Q1–5, 15: 9 (6) vs. 25 (7) vs. 17 (9) Intercourse satisfaction Q6–8: 5 (4) vs. 11 (3) vs. 8 (4) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n: 43 (phase I, 16; phase II, 27) WDAE: NR TAE: pts with at least 1 AE [phase I]; [phase II], (%): [31 vs. 56], [53 vs. 58] Application site reaction: [4 vs. 16], [2 vs. 10] Other penile pain: [20 vs. 30], [34 vs. 25] Prolonged erection: [2 vs. 0], [3 vs. 0] SAE: 0 Ascertainment of outcomes assessed: IIEF (Q1–5, 15; and Q9, 10; and Q6–8; and Q13, 14), Buckling test; grading system 0–3
Shokeir (1999) ^211^ Funding source: NR | N screened = NR N randomized = 60 (parallel design) IG1, n = 30 IG2, n = 30 CG = NA ITT analysis used for primary outcome: NR Inclusion: [underlined: men] 18 y or older, with ED of primarily organic aetiology, inability to achieve erection sufficient for intercourse at least 1 time during 3 mo before study period Exclusion: previous use of IC injections Data reported as IG1 vs. IG | Age, mean (sd): 55 (18) vs. 56 (17) y Co-morbidities: NR Previous ED treatment, n (%): 16 (53) vs. 17 (57); vacuum pumps, band therapy, hormones Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean (sd): 36 (8) vs. 38 (10) Underlying disease, n (%): Vascular disease: 9 (30) vs. 6 (20); diabetes: 15 (50) vs. 18 (60); surgery/ trauma: 3 (10) vs. 3 (10); other causes 3 (10) vs. 3 (10) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: IC PgE1(injection) IG2: IU MUSE IG1: Dose: 20 μg Duration: 3 mo Frequency: at least 1/wk Compliance: 33% IG2: Dose: 1 mg Duration: 3 mo Frequency: at least 1/wk Compliance: 83% Run In period: NR Wash out period: NR F/u duration: 3 mo | Primary outcome results: IG1 vs. IG2 Erection score of 4 and 5 in clinic, n (%): 27 (90) vs. 18 (60) Sexual intercourse (at least once) at home: 26 (87) vs. 16 (53) Other outcomes assessed: Ease of treatment Withdrawals/drop-outs/loss to f/u: n = 25, IG1 n=20 vs. IG2 n=5 WDAE, n: 9 (due to pain) vs. 0 IG1: IG2: 0 TAE, n (%): All AE, Urogenital pain 14 (47) vs. 2 (7); dizziness 0 vs. 2; urethral bleeding 0 vs. 1 SAE: 0 Ascertainment of outcomes assessed: Personal diaries, Erection Assessment Scale 0–5
Williams (1998) ^212^ Funding source: Grant from VIVUS Inc. Manufacturer of MUSE (Alprostadil (PGE_1_) in transurethral route) | N screened = 249 N randomized = 159 (64% of screened pts who achieved erection adequate for intercourse on test dose) IG, n = 78 CG, n = 81 ITT analysis used for primary outcome: ITT efficacy 44% Inclusion: men 18 y or older with primary organic ED 3 mo or longer in duration, inability to achieve erection for intercourse on all attempts for 3 mo before study, stable, heterosexual, monogamous relationship, willing to have intercourse 4/mo + use contraception Exclusion: NR Data reported for IG vs. CG | Age, mean (range): 57.3 (25–78) y vs. 57.3 (26–77) y Co-morbidities: NR Previous ED treatment, (%): 51 vs. 54 (constrictive bands, IC, vacuum, counseling) Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 59.6 (3–644) vs. 63.3 (4–417) mo Underlying disease: NR Psychogenic ED: NR Physiologic ED: Vascular disease: 33% vs. 41% Diabetes 18% vs. 15% Surgery/trauma: 24% vs. 21% Other organic (includes; alcohol or tobacco use; neurological diseases; medication adverse reaction): 24% vs. 24% Mixed ED: NR | IG1: Alprostadil (PgE1) transuretrhal pellet as per protocol CG: Placebo IG1: Dose: Escalating dose of 125, 250, 500 or 1000 μg Duration: 3 mo Frequency: at least 1/mo Compliance: 53 (68%) CG: Dose: Placebo Duration: 3 mo Frequency: as IG 1/mo Compliance: 64 (79%) Run In period: 3 mo Wash out period: NA F/u duration: 3 mo Other: Final patient selected dose distribution (μg), n (%): 1000 μg =103 (65%) 500 μg= 27 (17%) 250 μg =21 (13%) 125 μg =5 (5%) | Primary outcome results: EAS, score ≥ 4: in all pts, 159 (64%) Intercourse ≥ once during 3 mo, n (%): 46(69) vs. 8/73 (11%), p<0.001 Intercourse/ total injections: 390/ 763 (51) vs. 46/611 (7.5) CG Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 42 (26%) [n=25 vs. n=17] WDAE: 4 TAE: self reported AEs, n (%): Urogenital pain/ burning: 5 (6) vs. 0 Penile pain: 4 (5) vs. 1 (1) Testicular pain: 2 (3) vs. 0 Urethral bleeding/spotting: 1 (1) vs. 1 (1) Urinary tract infection: 0 vs. 0 Prolonged erection < 5 hr: 1 (1) two events vs. 0 Priapism (≥ 6 hr)= firbrosis= hypotension: 0 vs. 0 Dizziness: 2 (3) vs. 0 SAE: 0 Ascertainment of outcomes assessed: Erectile Assessment Scale (1=no response to 5=rigid erection) Comfort with therapy, intercourse rate, and AE by diary/self report

List of abbreviations: %=percent, ▴=increased, ▾=decreased, AE=adverse event, SAE=serious adverse event, BMI=body mass index, CC=controlled clinical trials, CG=comparator/control group, ctrls=controls, DM=diabetes mellitus, E_1_ IC=intracavernosal injection, ECG=electrocardiograms, ED=erectile dysfunction, EDV=end-diastolic velocity, f/u=follow-up, FMD=flow mediated dilation, GAQ=global assessment question, GEQ=global efficacy question, grp=group/s, HbA1C=haemoglobin, hr=hour(s), hx=history, IG=intervention group, IIEF= international index of erectile function (EF=erectile function, OF=orgasmic function, OS=overall satisfaction, SD=sexual desire), ITT=intent-to-treat (Y = yes, N = no, NR = not reported), IU=intraurethral, kg=kilograms, lbs=pounds, LUTS=lower urinary tract symptoms, M=male, max=maximum, mo=month(s), NA=not applicable, PADAM=partial androgen deficiency of the aging male, PgE_1_=Prostagladin, PRL=prolactin, PSA=prostate-specific antigen, RAU=rigidity activity unit, RCT=randomized control trial, SBP=systolic blood pressure, sign.=significant; TAE=total adverse events, TAU=tumescence activity unit, vs.=versus, WDAE=withdrawals resulting from adverse events, wk=week(s), yr=year(s).

Evidence Table C8. Topical Treatments of ED

Author Funding | N; study design; eligibility | Participants characteristics | Diagnosis details | Intervention | Outcomes
Cavallini (1991) ^213^ Funding source: NR | N screened = 51 N randomized = 33 (crossover design) IG1/IG2/CG = 33 (random order in each session) ITT analysis used for primary outcome: NR Inclusion: chief complaint of impotence Exclusion: psychogenic impotence; uncontrolled diabetes; thyroid, renal or hepatic disease; recent myocardial infarction; hypotension; use of organic nitrates or nitrites or of minoxidil within previous 4 mo | Age, mean (range): 58, 42–68) y Race: NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: DM 12 (36.4); arteriosclerosis 9 (27.3); hypertension 4 (12.1; pelvic fracture or surgery 6 (18.2); SCI 1 (3), multiple sclerosis 1 (1) Psychogenic ED: 0 Physiologic ED: 33 Mixed ED: 0 Other: NA | IG1: 10% topical Nitroglycerin paste IG2: 2% minoxidil topically to glans penis CG: placebo (lubricating gel) topically to glans penis IG1: Dose: 2.5 g Duration: NR Frequency: once/wk; applied to shaft Compliance (%): 100% IG2: Dose: 1 mL Duration: NR Frequency: one/wk applied to glans Compliance (%): 100% CG: Dose: 2.5 g Duration: NR Frequency: as IG2 Compliance (%): 100% Run In period: NR Wash out period: 1 wk F/u duration: outcomes were measured one hr post dosing each; trail duration 3 wks | Primary outcome results: Change in circumference of base of penis and in rigidity over baseline values, assessed a few minutes after drug application Circumference (mm), mean (sd): IG1: 9.5 (5.3) IG2: 17.2 (7.5) CG: 4.3 (4.0) Rigidity, mean % (sd); range: IG1: 28.2 (11.1), range 0–80% IG2: 40.0 (13.3), range 0–85% CG: 13.6 (10.7), range 0–18% Other outcomes assessed: Examination of cavernous penile artery flow with Doppler sonography Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE, n: pts with AE 17 (51.5); nitroglycerine 15 (45.5) vs. minoxidil 2 (6.1) vs. 0 Burning pain at application site, headache, hypotension SAE: 0 Ascertainment of outcomes assessed: RigiScan™ Rigidity Assessment System
Cavallini (1994) ^214^ Funding source: | N screened = NR N randomized = 132 cross over trial (data reported for n=116 completers) IG1, n = 39 IG2, n = 39 IG3, n = 38 CG, n = NA ITT analysis used for primary outcome: No Inclusion: pts with ED Exclusion: psycogenic, endocrine or pharmacological impotence, recent MI, hypotension, uncontrolled diabetes, liver or kidney disease, use of organic nitrates, nitrates or minoxidil in the previous 4 mo | Age, mean (range): 58 (42–71) y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Initial body weight: NR | Concomitant medications: NR Duration of ED: at least 6 mo Underlying disease, n (%): diabetic neuropathy 11 (9.5); SCI 3 (2.6); pelvic fracture 6 (5.2), pelvic surgery 12 (10.3); diabetic angiopathy 18 (15.5); atherosclerosis 27 (23.3); hypertension 16 (13.8); DM 10 (8.6) Psychogenic ED: None Physiologic ED: Neurogenic (n=34), arterial (n=61) Mixed ED n=12 | IG1: minoxidil - nitroglycerine - placebo IG2: nitroglycerine - placebo - minoxidi IG3: placebo - minoxidil - nitroglycerine IG1: minoxidil (2%) Dose: 1 ml Duration: 2 mo Frequency: twice/ d Compliance (%): NR IG2: nitroglycerine (10%) Dose: 2.5 g Duration: 2 mo Frequency: twice/ d Compliance (%): NR CG: placebo Dose: 2.5 g Duration: 2 mo Frequency: twice/ d Compliance (%): NR Run In period: Wash out period: F/u duration: 6 mo | Primary outcome results: N (%) pts with positive response (prompt erection, absence of penis flexure during intercourse, maintaining full erection until ejaculation): 51 (44) vs. 24 (20.7) vs. 2 (1.7%), p < 0.01 (IG1 vs. IG2 and IG2 vs. CG) Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u, n (%): 16 (13.8) WDAE NR TAE, n (%): pts (IG1 vs. IG2 and IG2 vs. CG) = 7 (6.0) vs. 52 (44.8) vs. 0, p < 0.01 (IG1 vs. IG2 and IG2 vs. CG), p < 0.05 (IG1 vs. CG) SAE: NR Ascertainment of outcomes assessed: Questionnaire
Claes (1992) ^215^ Funding source: NR | N screened = NR N randomized = 50 (cross over) IG/ CG, n = 50 (random order of active tx or placebo) ITT analysis used for primary outcome: No Inclusion: men with ED (defined as having erections insufficient in rigidity/ or duration for penetration during intercourse) Exclusion: hx of MI; hypotension, use of organic nitrates within previous 6 mo | Age, mean (range): 56 ( Race: NR Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant Medications: NR Duration of ED: NR Underlying disease: NR Physiologic ED: NR Psychogenic ED: NR Mixed ED: NR | IG: Nitroglycerine (Deponit (TM)) delivered by transdermal therapeutic system CG: placebo IG: Dose: 10 mg Duration: 24 hr/ dose: 3 night Frequency: 3/dose (active or placebo) Compliance (%): CG: Dose: NA Duration: as IG Frequency:as IG Compliance (%): Run In period: NR Wash out period: NR F/u duration (both on and off treatment): NR | Primary outcome results: Excluded from analysis Rigidity >70% (normal): n=4 (9.8%) No erection, <70% rigidity: n=7 (17.1%); Change in rigidity from baseline, n (%); mean% (sd), range, IG: Base ▴ in n= 21 (51.2); 14 (3), 1–21% ▾ in n= 6 (14.6); 6 (2), 1–11 No change in n = 3 (7.3) Tip ▴: n=23 (56.1); 17 (4), 1–27% ▾: n=5 (12.2); 8 (3), 1–14% No change n = 2 (4.9) Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u, n (%): 9 (51.2) WDAE: 4 TAE: 0 SAE: 0 Ascertainment of outcomes assessed: RigiScan ambulatory unit in laboratory (pts were evaluated at baseline with IC injection of papaverine 40–80 mg)
Diamond (2004) ^216^ Funding source: NR | N screened = NR N randomized = 24 IG/ CG, n= 24 (3 way cross over, two active tx of high or low dose, and placebo) ITT analysis used for primary outcome: yes Inclusion: men 18 or older, diagnosis of ED, treated successfully with Viagra within 6mo, current users of Viagra Exclusion: ED caused by untreated endocrine disease, penile anatomic deformations, prostatic disorders, evidence of clinically sign. hepatic, renal, cardiovascular, psychiatric or CNS disease (stroke or SCI) | Age, mean (se): 50.9 (8.1); range 38–64 Race, n (%): White 16 (66.7) Black 6 (25.0) Hispanic 1 (4.2) Other 1 (4.2) Co-morbidities, n (%): DM 2 (8); hypertension 4 (17); hyperlipidemia 3 (13) Previous ED treatment: NR Smoking status: N 14 (59) Body weight, mean (se): 89.1 (15.2) Range 61.3–120.8 | Concomitant medications: viagra (all pts) Duration of ED, mean: 6.2 y Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1/2: cyclic heptapeptide melanocortin analog PT-141) delivered intranasally in 2 doses or placebo CG: placebo IG1/2: Dose: 7 (IG1) or 20 mg (IG2) Duration: 12 hrs Frequency: 3 times Compliance (%): 100 CG: Dose: NA Duration: 12 hrs Frequency: 1× Compliance (%): 100 Run In period: NA Wash out period: NA F/u duration (both on and off treatment): NR | Primary outcome results: Duration of erection (min) with rigidity ≥ 60%: Base, mean (se): 26.0 (5.52) vs. 53.8 (8.54) vs. 18.5 (3.72) Tip, mean: 6.3 vs. 23.8 vs. 7.2 List (narrative) other outcomes assessed: plasma concentrations of study drug (ng/ml), mean: IG1=38.8; IG2 = 122.1 Withdrawals/drop-outs/loss to f/u [N and or %]: 0 WDAE (N and/or %): 0 TAE, n (%): AE in 5% or more of pts, 7 mg vs. 20 mg vs. placebo: 9 (37.5) vs. 8 (33.3) vs. 3 (12.5); including: Nausea = 1 (4.2) vs. 4 (16.7) vs. 0 Headache = 1 (4.2) vs. 0 vs. 0 Feeling hot = 2 (8.3) vs. 0 vs. 1 (4.2) Somnolence = 1 (4.2) vs. 0 vs. 1 (4.2) Flushing = 4 (16.7) vs. 4 (16.7) vs. 0 SAE: 0 Ascertainment of outcomes assessed: RigiScan, blood tests, physical exam
Foldvari (1998) ^217^ Funding source: NR | N screened = NR N randomized = 5 in crossover design IG1/IG2/IG3/CG, n= 5 ITT analysis used for primary outcome: NR Inclusion: ED caused by vascular impairment; and previous response to 10 or 20 μg PgE_1_ IC; with no venous leak Exclusion: NR Note: this study compared the in vitro transdermal absorption of PgE1 to in vivo efficacy of the medication in ED pts | Age, range: 54–70 y Race (%): NR Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C)(%): NR Previous ED treatment: all pts PgE_1_ IC, 10–20 μg Smoking status: NR Initial body weight: NR | Concomitant medications: NR Duration of ED (yr): NR Underlying disease (diagnosis) (N or % of diseased/grp): NR Psychogenic ED: 0 Physiologic ED: Vascular 5 (100%) Mixed ED: NR | IG1: topical PgE_1_ + placebo IG2: PgE_1_ + calcium thioglycolate+ placebo IG3: PgE_1_ + methyl-salicylate+ placebo CG: placebo IG1-3: Dose: PgE1=1.5 g (all grps); Calcium thioglycolate= 1% (IG2); Methyl-salicylate=2% (IG3) Duration: NR Frequency: single dose/ intervention Compliance (%): 100% CG: Dose:1.5 g soy phosphatidylcholine 15% Duration: NA Frequency: as IG Compliance (%): 100% Run In period: NR Wash out period: at least 1 wk F/u duration: 45 min post dosing | Primary outcome results: Quality of erection: no dose reached threshold for erection. PSV (cm/s) at 0 min vs. 45 min, mean (sd): IG1 = 0 vs.12.3 (1.1) IG2 = 5.5 (2.6) vs. 1.3 (0.8) IG3 = 0 vs. 14.2 (4.4) CG = 2.0 (1.9) vs. 7.7 (6.8) Max peak flow Velocity: IG3 =32 cm/s Other outcomes assessed: Steady State Flux (mg/cm^2^/ hr) of PgE_1_: IG3 (0.191) > b (0.083) > IG2 (0.010) > CG Permeability coefficient (cm/hr × 10^-4^) (i.e. rate + extent of penetration): IG3 (3.82) > IG1 (1.66) > CG (0.84) > IG2 (0.10); Total amount of PgE_1_ absorbed: IG3 = 3.5 μg (microgram)/cm^2^ Withdrawals/drop-outs/loss to f/u: IG1 1 vs. IG2 2 vs. IG3 0 vs. CG 2 WDAE: NR TAE: 0 SAE: NR Ascertainment of outcomes assessed: Peak Systolic Flow Velocity (arterial) by Duplex color Doppler: every 15 min for1 hr at 60 degree angle Normal at > 25 cm/s
Goldstein (2001) ^218^ Funding source: MacroChem Co. sponsor for study drug. Some authors supported by MacroChem Co., Pfizer, Bayer, TAP, Zonagen and Schering Plough | N screened = 62 N randomized = 60 IG, n = 30 CG, n = 32 ITT analysis used for primary outcome: yes (n=60) Inclusion: male 21 or older; with ED of 6 mo or longer (decrease or absent of morning erection Exclusion: Previously enrolled in a Topiglan study; untreated endocrine or Peyronie's disease; radical prostatectomy; CAD; hypertension (Screening exclusion criteria: Placebo+ Erotic movie at 30 min from onset + vibrator at 45 min and then discontinued at 60 min. If erectile response ≥ 70 degree angle or grade 3 as rated by pts were withdrawn) | Age, range: 24–78 yr Race (%): NR Co-morbidities: NR Previous ED treatment: all Oral (Sildenafil); PgE1 in IC or IU route or PgE1 + papaverine + phentolamine IC or papaverine + phentolamine IC tx Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED, %: Vascular: 97% Mixed ED: NR | IG1: Topiglan 1% (PgE1 formula)+ VS. + vibration CG: Placebo +VS + vibration IG: Dose: 0.25 ml Duration: Single Frequency: once Compliance: 100% CG: Dose: 0.25 ml (formulation similar to Topiglan without PgE1) Duration: Single Frequency: 2 Compliance: 100% Run In period: 7 d Wash out period: NA F/u duration: 2 wks (VS and vibration stopped at 60 min post dosing, outcome measured at 90 min post dosing) | Primary outcome results: Erection rigidity measured by angle of erection: IG1 vs. CG 44.5° (3.8)° vs. 33.5° (3.4)° (p= 0.033) Mean change of angle from baseline: 24.2° vs. 13.5° (p= 0.039) Rigidity as per Investigator assessment: Overall IG1 vs. CG: p= 0.003 Erection sufficient for vaginal penetration, n (%): 12 (38) vs. 2 (6.9), p =0.005 No tumescence, n (%): 3 (9.7) vs. 8 (27.6) Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: 2 (3.2) WDAE: 0 TAE: 3 vs. 0 Conjunctivitis: 2 vs. 0 Hypotension: 1 vs. 0 SAE: 0 Ascertainment of outcomes assessed: Penile angle: measured by placing a protractor next to penis in standing position. Measure of angle at vertical axis; erection rigidity scale investigator assessed at 15–90 min (1–5)
Gomaa (1996) ^219^ Funding source: no additional funding; no conflict of interest | N screened = NR N randomized = 36 ITT analysis used for primary outcome: NR IG, n = 36 CG, n = 36 Inclusion: Pts whose chief complaint was ED aged 31–65 y Exclusion: Pts with hypotension or glaucoma | Age, median (range): 48 (31–65) y Race (%): NR Co-morbidities (unrelated to disease): NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: mean arterial flow = IG1: 0.06 (0.02) vs. CG: 0.06 (0.02) | Concomitant medications: NR Duration of ED, median (range): 39 (5–72) mo Underlying disease: DM, hypertension, anxiety, depression, and surgery Psychogenic ED, n (%): 9 (25) Physiologic ED, n (%): 8 (22.2) (neurogenic), 7 (19.4) (arterial insufficiency) Mixed ED, n (%): 8 (22.2) | IG: Topical cream CG: Placebo cream IG: Topical cream (3% aminophylline, 0.25% isosorbide dinitrate, 0.05% co-dergocrine mesylate) Dose: 2 g/d Duration: 7 d Frequency: once Compliance (%): NR CG: Placebo (lubricating gel) Dose: 2 g/d Duration: 7 d Frequency: once Compliance (%): NR Run In period: NR Wash out period: NR F/u duration (both on and off treatment): 7 d | Primary outcome results: IG vs. CG Mean arterial flow: 0.25 (0.1) vs. 0.08 (0.07), p (between-arm) = NR, p (within-arm for IG1) < 0.001 and p (within-arm for CG) > 0.05. Erection sufficient for successful intercourse, n: 21 vs. 3, p < 0.001 Partial erection, n: 2 vs. 0, p = NR No response, n: 11 vs. 33, p = NR (3/9 pts with Psychogenic impotence reported improvement with both creams) Other outcomes assessed: erection outcome reported for three etiology type Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE: No prolonged erection, priapism, CVD, headache SAE: NR Ascertainment of outcomes assessed: penile tumescence and arterial flow in laboratory measures; other outcomes from pts diary Other: the active cream was most effective in pts with psychogenic and neurogenic ED
Gramkow (1999) ^220^ Funding source: The Bryde Nielson Foundation | N screened = NR N randomized = 19 (cross-over design with 2 part study A, B) Laboratory study: IG/ ICG, n = 19 Home study: IG/ ICG, n = 18 ITT analysis used for primary outcome: no Inclusion: unable to complete intercourse, some erectile response to IC injection of 30 mg papaverine, with penile-brachial index > 60% Exclusion: Arterial hypotension, arterial insufficiency < 60 %, former coronary occlusion, hypersensitivity to nitroglycerine, used any kind of drug containing nitroglycerine within last 2 mo. | Age, median (range): 56 (39-5-65) y Race (%): NR Co-morbidities (unrelated to disease): cancer (rectum, bladder), peyroni plaque, slipped disc, multiple sclerosis, chronic prostatitis Previous ED treatment: IC injection of 30 mg papaverine Smoking status, n (%): smokers 7 (39) Initial body weight: NR | Concomitant medications: various medication Duration of ED (yr): NR Underlying disease: no specific cause reported Psychogenic ED: 12 Physiologic ED: 5 Mixed ED: 1 Other: N/A | IG: nitroglycerine plasters, topical absorption +VS CG: placebo of nitroglycerine plasters, topical absorption+ VS IG: Dose: 10 mg Duration: lab period 2 hr/session; home period varied in each pts Frequency: lab study: twice (1/d); home study 6 times Compliance (%): lab 100%; home study 94.4% used all plasters CG: Dose: 10 mg Duration: as IG Frequency: as IG Compliance (%): lab 100%; home study: 66.7% used all plasters Run In period: NR Wash out period: NR F/u duration: NR | Primary outcome results: Laboratory period Penile rigidity: (only figure provided within text but N of patients in each % range category clear) No effect: 11 vs. 12 Poor effect: 1 vs. 1 Moderate effect: 3 vs. 3 Good effect: 2 vs. 0 Excellent effect: 1 vs. 2 No sign tx effect found in IG vs. CG p=0.7656 Home period Median score (scale 1–3), median range: 1–2 vs. 1–2.5 Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u: 1 (5.3) RigiScan data could not be collected during lab test WDAE: 1 vs. 0 (severe pain with plaster) TAE: IG: headache 35 cases; 23 cases of smarting pain at the application site SAE: NR Ascertainment of outcomes assessed: Laboratory study: RigiScan monitoring; home study: questionnaire (3 item point Scale; 1= no effect; 3= good effect)
Le Roux (1999) ^221^ Funding source: NR | N screened = NR N randomized = 14 IG, /CG, n = 14 ITT analysis used for primary outcome: NR Inclusion: pts with erectile failure who previously responded to IC injections Exclusion: NR | Age, mean (range): 44 (23–57) y Race (%): NR Co-morbidities: NR Previous ED treatment: all had tx with IC injection 14 (100%) Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease, n: pelvic fracture (n=1), spinal paraplegia from tuberculosis (n=1), spinal myelopathy of unknown aetiology (n=1), vasculogenic impotence (n=1) Psychogenic ED, n (%): 10 (71.4) Physiologic ED, n (%): 4 (28.6) Mixed ED: NR | IG: vasoactive cream (aminophylline, co-dergocrine mesylate, isosorbide dinitrate) CG: placebo (gel) IG1: Dose: 2 mL syringes (aminophylline 3%, co-dergocrine mesylate 0.05%, isosorbide dinitrate 0.25%); total applications =77 Duration: NR Frequency: 8 application with each cream used alternatively Compliance (%): NR CG: Dose: NA Duration: NR Frequency: as IG; total applications =76 Compliance (%): NR Run In period: NR Wash out period: NR F/u duration: 6 wks | Primary outcome results: Penile response 77 vs. 76 applications in n=8: Erection adequate for intercourse: 3 (3.9) vs. 4 (5.3) [all in one pt] Partial response: 13 (16.9) vs. 13 (17.1) No response: 61 (79.2) vs. 59 (77.6) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): 6 (43%) did not complete the trial WDAE: 0 TAE: 0 SAE: 0 Ascertainment of outcomes assessed: Penile response by grading system (good, partial, no response) by pts diary
Padma-Nathan (2002) ^222^ Study a Funding source: NedMex Inc. | N screened = NR N randomized = 161 IG1, n = 42 IG2, n = 39 IG3, n = 40 CG, n = 40 ITT analysis used for primary outcome: No Inclusion: ED ≥ 3mo, monogamous & stable relationship with consenting female partner, mild-moderate ED classified by IIEF-EF domain (score 14–21) Exclusion: ED caused by untreated endocrine disease, clinically sign. renal or hepatic disease, use of prescribed or over the counter medication, supplements, or devices for ED | Age, mean (sd): 56.5 (7.1), range 21–65 y Race, %: IG vs. CG White 86 vs. 75; African-American 7.3 vs. 10; Asian 0 vs. 2.5; Hispanic 5.8 vs. 12.5; Other 2.6 vs. 0 Co-morbidities (unrelated to disease): NR Previous ED treatment: NR Smoking status: NR Body weight, mean (sd): 93.4 (37.3) kg | Concomitant medications: NR Duration of ED: 95% of pts had ED for longer than 1 y; 5% under 1 y Underlying disease, %: CVD 54.3%; DM 15.7% Psychogenic ED: NR Physiologic ED: 100% Mixed ED: NR | IG1-3: Topical alprostadil cream CG: Placebo cream IG1: Dose: IG1= 0.05 mg, IG2= 0.1mg, IG3= 0.2 mg Duration: 6 wks Frequency: 3 application in 3 wks Compliance (%): 100 CG: Dose: NA Duration: 6 wks Frequency: as IG Compliance (%): 100 Run In period: NR Wash out period: NR F/u duration: 6 wks | Primary outcome results: IIEF- EF, change from baseline, mean (sd): IG: 1.8 (1.1) vs. 0.7 (1.2) vs. 3.7 (1.2) CG: -0.8 (1.1) Total IIEF score, change from baseline, mean (sd): IG: 4.7 (2.3) vs. 1.4 (2.4) vs. 7.2 (2.5) CG: -1.7 (2.2) SEP-Q3/Q1 (penetration success rate), mean (sd): IG: 69.4 (34.2) vs. 69.1 (39.3) vs. 82.9 (24.6) CG: 55.3 (40.0) GAQ, % improved: IG: 80% vs. 70% vs. 93% CG: 54% Other outcomes assessed: Other IIEF domains Withdrawals/drop-outs/loss to f/u: IG 22 (18.2) vs. CG 0 WDAE, n (%): IG 6 (14.3) vs. 7 (17.9) vs. 9 (22.5), CG 0 (urogenital pain) TAE, n (%): IG 28 (66.7) vs. 26 (66.7) vs. 31 (77.5), CG 21 (52.5) SAE: 0 Ascertainment of outcomes assessed: IIEF, GAQ, SEP
Padma-Nathan (2002) ^222^ Study b Funding source: NedMex Inc. | N screened = NR N randomized = 142 IG1, n = 37 IG2, n = 35 IG3, n = 35 CG, n = 35 ITT analysis used for primary outcome: No Inclusion: ED ≥ 3mo, monogomous & stable relationship with consenting female partner, severe ED classified by IIEF EF Domain score (score < 14) Exclusion: ED caused by untreated endocrine disease, clinically sign. renal or hepatic disease, use of prescribed or over the counter medication, supplements, or devices for ED | Age, mean (sd): 55.6 (8.0), range: 21–70 y Race (% by respective grp): Caucasian 88.8%; African-American 4.3%; Asian 0.7% (only in IG2); Hispanic 4.8%; Other 2.1% Co-morbidities (unrelated to disease): NR Previous ED treatment: NR Smoking status: NR Body weight, mean (sd): 92.6 (36.8) kg Other: IIEF-EF, mean (sd): IG 6.7 (3.6); CG 7.8 (3.5) | Concomitant medications: NR Duration of ED (% by respective grp): .25 –1 yr 7.25%; > 1 y 92.75% Underlying disease, %: CVD 58.25% (slightly lower in IG1); DM 50.75 (slightly higher in IG1) Psychogenic ED: NR Physiologic ED: 100% Mixed ED: NR | IG1-3: Topical alprostadil cream CG: Placebo cream IG1: Dose: IG1= 0.1 mg, IG2= 0.2mg, IG3= 0.3 mg Duration: 6 wks Frequency: 3 application /3 wk Compliance (%): 100 CG: Dose: NA Duration: 6 wks Frequency: as IG Compliance (%): 100 Run In period: NR Wash out period: NR F/u duration: 6 wks | Primary outcome results: Data reported for IG n=34, 29, 29; CG n=35 IIEF, change from baseline, mean (sd) EF domain IG: 6.29 (1.38) vs. 6.49 (1.48) CG: 2.67 (1.34) Total IIEF score: IG: 11.47 (2.74) vs. 12.96 (2.96) vs. 17.65 (2.92); CG: 6.24 (2.67) SEP-Q3/Q1 (penetration success rate), mean (sd): IG: 32.3 (18.0) vs. 36.2 (29.3) vs. 38.6 (22.8); CG: 15.6 (17.2) GAQ, % improved: IG: 59% vs. 76% vs. 83%; CG 26% Other outcomes assessed: Other IIEF domain scores Withdrawals/drop-outs/loss to f/u, n (%): IG 15 (14) vs. CG 0 WDAE, n (%): IG 1 (3) vs. 7 (20) vs. 8 (23); CG 0 TAE, n (%): IG 11 (30) vs. 21 (60) vs. 18 (51); CG 4 (11) SAE: 0 Ascertainment of outcomes assessed: IIEF, SEP, GAQ
Padma-Nathan (2006) ^223^ Funding source: NexMed (study drug supply); co-author a paid consultant of NexMed | N screened = N randomized = 1732 IG1, n = 434 IG2, n = 430 IG3, n = 434 CG, n = 434 ITT analysis used for primary outcome: yes (pts with at least one study medication) Inclusion: men at least 21 y, in a stable relationship, and hx of ED of at least 3 mo in duration Exclusion: ED due to untreated endocrine disease or sing penile pathology (i.e. penile fibrosis, Peyronie disease) | Age, mean (se): 61 (0.47) y Race: White 86%; Black 8.3%; Hispanic 3.9%; other 1.8% Co-morbidities, n (%): DM 305 (17.6); cardiac 503 (29); prostatectomy 220 (12.7) slightly higher in IG1; hypertension 783 (45.2) Previous ED treatment: sildenafil [failures 352 (18.8)] Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): NR Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG1-3: Alprostadil topical cream CG: Placebo cream IG1-3: Dose: IG1=100 μg, IG2 = 200 μg, IG3=300 μg Duration: 12 wks Frequency: up to 24 applications (2/wk) Compliance: NR CG: Dose: Duration: 12 wks Frequency: as IG Compliance: NR Run In period: 4 wks drug free Wash out period: F/u duration: 16 wks | Primary outcome results: IIEF-EF, LS mean change from baseline (se): IG: 1.6 (0.34) vs. 2.5 (0.34) vs. 2.4 (0.34), CG -0.7 (0.34) SEP, LS mean % change form baseline (se): SEP-2: IG 2.9 (1.63) vs. 5.1 (1.65) vs. 7.2 (1.65), CG -4.5 (1.65) SEP-3: IG 7.0 (1.61) vs. 13.8 (1.63) vs. 9.1 (1.63), CG 0.4 (1.64) GAQ, % improved: IG 40% vs. 47% vs. 52%, CG 20% Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): WDAE, n (%): 46 (2.7) TAE, n (%): 198 (45.6) vs. 267 (62.1) vs. 292 (67.3) vs. CG 54 (12.4) Body as whole: IG 5 (1.2) vs. 1 (0.2) vs. 0 CG 1 (0.2); nervous system IG 5 (1.2) vs. 7 (1.6) vs. 11 (1.2), CG 1 (0.2) Skin rash: IG 2 (0.5) vs. 5 (1.2) vs. 2 (0.5) CG 1 (0.2); urogenital system: IG 186 (42.9) vs. 254 (59.1) vs. 279 (64.9) CG 51 (10.6) SAE, n (%): IG 0, CG 1 (0.2) died due to cardiac arrest Ascertainment of outcomes assessed: IIEF-EF; SEP; GAQ
Steidle (2002) ^224^ Funding source: NexMed manufacturer of Alprostadil topical | N screened = 303 N randomized = 265 from 2 Phase II RCT, 12 settings IG1, n = 36 IG2, n = 66 IG3, n = 61 IG4, n = 29 CC, n = 73 ITT analysis used for primary outcome: NR Inclusion: men 21–75 y, with diagnosed ED of at least 3 mo in duration, and IIEF score of 21 or less Exclusion: NR | Age, mean (sd): 82.1 (7.4) y Race (%): White: 84.7; African American: 6.5; Asian 0.6; Native American 1.9; Hispanic 6.6; Other 1.2 Co-morbidities (unrelated to disease): NR Previous ED treatment: NR Smoking status: NR Body weight, mean (sd): 92.5 (38) kg | Concomitant medications: NR Duration of ED (yr): 0.25–1 yr: 7 % >1yr: 93 % Underlying disease, %: CVA 56.8; DM 37% Psychogenic ED, n (%): IG 48 (25) vs. CG 18 (25) Physiologic ED, n (%): IG 72 (37.5) vs. CG 28 (38) Mixed ED, n (%): IG 72 (37.5) vs. CG 27 (37) Other: Mean IIEF-EF domain, mean (sd): 12 (4.8) | IG1-4: Alprostadil (PgE_1_) topical CG: Placebo IG1-4: Dose: 0.1ml IG1=50 μg IG2=100 μg IG3=200 μg IG4=300 μg Duration: 6 wks Frequency: 10 doses Compliance (%): NR CG: Dose: 0.1 ml placebo Duration: 6 wks Frequency: as IG Compliance (%): NR Run In period: NR Wash out period: NR F/u duration (both on and off treatment): 6 wks | Primary outcome results: IIEF-EF change from baseline, mean (sd): 3.36 (1.3), 3.40 (0.88, 5.34 (0.92), 9.44 (1.43) vs. 0.98 (0.84) GAQ, % improved: IG1 p= 0.028, IG2 p= 0.007, IG3 p< 0.001 or IG4 p<0.001 vs. CG SEP-Q3, %: 59.4 (6.3), 53.4 (4.4), 62.6 (4.5), 66.8 (7.1) vs. 42.6 (4.2) Other outcomes assessed: self evaluation of erection; SEP Q3/Q4 Withdrawals/drop-outs/loss to f/u, n (%): IG 0, 2 (3), 2 (3), 6 (21) vs. CG 3 (4); all IG 10 (5.2) vs. CG 3 (4.1) WDAE, n (%): IG 6 (14), 8 (11), 16 (21), 7 (20) vs. CG 1 (1) TAE, n (%): reported only if ≥ 3% (n) 214 SAE: Near Syncopal episode for approximately 10 minutes: 1(1.3%) in IG3 Ascertainment of outcomes assessed: IIEF-EF; GAQ; SEP Patient self-evaluation of erection (PSAE), score 1–5
Yonessi, M (2005) ^225^ Funding source: research council of Mazandaran University of Medical Sciences, Sari, Iran | N screened = 94 N randomized = 80 IG1, n = 40 CG, n = 40 ITT analysis used for primary outcome: NR Inclusion: ED Exclusion: anatomical defects of penis or other sexual disorders; spinal cord injury; major psychiatric disorder; poorly controlled diabetes; stroke; heart attack within 6 mo; treatment with organic nitrate; active peptic ulcer disease; migraine; vision disorders; allergic rhinitis | Age, mean (range): 47.2 (26–63) vs. 50.8 (37–65) y Race (%): NR Co-morbidities (unrelated to disease): NR Previous ED treatment: NR Smoking status: NR Initial body weight: NR | Concomitant medications: NR Duration of ED, mean (range): 1.4 (0.6–2.8) vs. 1.5 (0.6–3.0) Underlying disease: NR Psychogenic ED: 23 (57) vs. 24 (60) Physiologic ED: 17 (42) vs. 16 (40) Mixed ED: 0 | IG: 1% sildenafil topically to glans penis + placebo tablet CG: placebo topically to glans penis + sildenafil tablet IG1: Dose: 0.5 g 1% sildenafil gel + placebo tablet Duration: NR Frequency: NR Compliance (%): 100% CG: Dose: 100 mg oral sildenafil and placebo gel Duration: NR Frequency: NR Compliance (%): 100% Run In period: NR Wash out period: NA F/u duration: up to 2 wk Other: tablets were taken 1 hr before sexual activity | Primary outcome (EF): Erection (complete, moderate, none) and onset of erection, n (%): Full erection: 5 (12.5) vs. 28 (70.0) Moderate erection: 5 (12.5) vs. 6 (15.0) None: 6 (15) vs. 30 (75.0) Onset of erection (full E), mean (sd): IG1: 7.4 (3.6) vs. 37.8 (14.9) min Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: 0 WDAE, n (%): 0 TAE, n (%): pts with AE, 4 (10) vs. 4 (8) including headache in IG, headache, dyspepsia, visual disturbances in CG SAE: 0 Ascertainment of outcomes assessed: NR

List of abbreviations: %=percent, ▴=increased, ▾=decreased, AE=adverse event, SAE=serious adverse event, BMI=body mass index, CC=controlled clinical trials, CG=comparator/control group, ctrls=controls, DM=diabetes mellitus, E_1_ IC=intracavernosal injection, ECG=electrocardiograms, ED=erectile dysfunction, EDV=end-diastolic velocity, f/u=follow-up, FMD=flow mediated dilation, GAQ=global assessment question, GEQ=global efficacy question, grp=group/s, HbA1C=haemoglobin, hr=hour(s), hx=history, IG=intervention group, IIEF= international index of erectile function (EF=erectile function, OF=orgasmic function, OS=overall satisfaction, SD=sexual desire), ITT=intent-to-treat (Y = yes, N = no, NR = not reported), IU=intraurethral, kg=kilograms, lbs=pounds, LUTS=lower urinary tract symptoms, M=male, max=maximum, mo=month(s), NA=not applicable, PADAM=partial androgen deficiency of the aging male, PgE_1_=Prostagladin, PRL=prolactin, PSA=prostate-specific antigen, RAU=rigidity activity unit, RCT=randomized control trial, SBP=systolic blood pressure, sign.=significant; TAE=total adverse events, TAU=tumescence activity unit, vs.=versus, WDAE=withdrawals resulting from adverse events, wk=week(s), yr=year(s).

Evidence Table C9. Testosterone Treatment of ED

Author Funding | N; study design; eligibility | Participants characteristics | Diagnosis details | Intervention | Outcomes
Adel (2006) ^226^ Funding source: NR | N screened = NR N randomized = 89 IG, n = 45 CG, n = 44 ITT analysis used for primary outcome: NR Inclusion: men with 5 or more consecutive mo of ▾ libido and quality of sexual erections; 2 or more morning total T <300 ng/dl (plasma free T was not entry criterion); normal rectal examination; PSA <4 ng/ml; urine flow rate of 12 ml/s or greater Exclusion: generalized skin disease that could affect T absorption; body weight < 7% or above 140% of ideal weight; hx of alcohol or drug abuse; hypotension; primary hypogonadism | Age, mean (sd): 54 (12), range35–65 y Race: NR Co-morbidities, n (%): DM, hypertension, anxiety and depression (no numeric data provided) Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): Duration of ED: NR Underlying disease, n (%): various aetiologies (no specific cause) Psychogenic ED, n (%): 30 (33.7) Physiologic ED, n (%): 34 (38.2); vascular 18 (20.2), neurogenic 16 (18), Mixed ED, n (%): 25 (28.1) | IG: Testosterone cream CG: Placebo cream IG: Dose: 2 g cream containing testosterone 0.8%, isosorbide dinitrate 0.5% and co-dergocrine mesylate 0.06% Duration: 2 mo Frequency: 2/d on right upper arm shuoulder Compliance: NR CG: Dose: 2 g lubricating gel Duration: as IG Frequency: as IG Compliance: NR Run In period: Wash out period: at least 4 wks in pts with oral or Injectable T tx F/u duration: 2 mo (fu every 15 d), last measure of RigiScan at 60 min post dosing | Primary outcome results: Result in bracket correspond to psychogenic, vasculogenic, neurogenic and mixed etiology sub-grps) RigiScan results, IG vs. CG: - Full erection: 18% vs. 0 [11, 1, 3, 3% vs. 0] - Partial erection: 53% vs. 6% [3, 5, 5, 4% vs. 2, 1, 2, 1%] - Tumescence: 3% vs. 2% [1, 0, 0, 2% vs. 1, 0, 1, 2%] - No response: 7% vs. 36% [1, 0, 0, 2% vs. 11, 8, 5, 12%] Pts diary results: - Full erection with successful intercourse: 40% vs. 0 - Partial erection insufficient for intercourse: 37% vs. 0 - Spontaneous erection: 38% vs. 0 Other outcomes assessed: serum T concentration, sign increase with active cream compare to baseline and vs. CG Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): NR TAE, n (%): NR; skin irritation 1 (1) vs. 0; headache 11% vs. 0; no priapism SAE, n (%): 0 Ascertainment of outcomes assessed: RigiScan post dosing in laboratory (5, 10, 15, 30, 60 min); pts diary every 15 d
Aversa (2003) ^227^ Funding source: Ministro dell'Universita e della Ricerca Scientifica e Tecnologica | N screened = 105 (reference sample) N randomized = 20 IG, n = 10 CG, n = 10 ITT analysis used for primary outcome: N Inclusion: arteriogenic ED (reduced PSV, but normal end systolic velocity) ED lasting 6 mo or longer. stable relationship, normal ECG, no hx of haematological or prostate dx, no antiandrogen drugs ingestion and response to Sildenafil scored as < 24 on the EF score of the IIEF; serum testosterone values between 10–13 nmol/l and serum free testosterone values between 200–300 pmol/l; no response to past T tx (100 mg) on 6 consecutive attempts Exclusion: pts with T levels in hypogonadal range (< 10 nmol/l) | Age, mean (sd): 54 (2) vs. 56 (4) Race (%): NR Co-morbidities, n: Systemic hypertension 3 vs. 4; DM type 2: 3 vs. 2; Cardiovascular disease: 3 vs. 2; Dyslipidaemia: 5 vs. 3 Previous ED treatment: NR BMI, mean (sd): 23 (2) vs. 24 (2) kg/m^2^ Smoking status, n: 6 vs. 6 Body weight: NR | Concomitant medications: Pts using less than 2 medications, n 3 vs. 6; using more than 2 medications: 4 vs. 7 Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: 20 Mixed ED: NR Other: Measurement of flow parameters on cavernous arteries (Measured in morning after standardized pharmacostimulation using 10 μg PgE1 with option of additional re-dosing of 10 μg PgE1 + 1 mg phentolamine), | IG1: Testosterone (patch) + Viagra CG: placebo (patch) + Viagra IG: Dose: 5 mg testosterone + 100 mg Viagra Duration: 1 mo Frequency: patch (daily), Viagra as needed (max of 20 tablets) Compliance: 100% CG: Dose: placebo + 100 mg Viagra Duration: 1mo Frequency: placebo (daily), Viagra as needed (max of 20 tablets) Compliance: 100% Run In period: NR Wash out period: NR F/u duration: 1 mo | Primary outcome results: IG vs. CG, mean (sd) IIEF-EF (>24) baseline: 14 (1) vs. 13 (1); post tx: 22 (2) vs. 14 (0.7) IIEF-intercourse satisfaction: (0–15), baseline: 7 (1) vs. 8 (2); post tx: post tx: 12 (2) vs. 8 (1) GAQ, (% yes): 80 vs. 10 PSA, baseline: 1 (0.7) vs. 1 (0.8); post tx: 2 (1) vs. 1 (0.8) Free T (200–700 pmol/l, baseline: 251 (17) vs. 236 (22) vs. 473 (40) vs. 256 (19) Other outcomes assessed: Hormonal and biochemical outcomes; IIEF domains of SD, OF, OS; LH, total T Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE: 0 SAE: 0 Ascertainment of outcomes assessed: IIEF; GAQ
Boyanov (2003) ^228^ Funding source: NR | N screened = NR N randomized = 48 (Open-label trial) IG, n = 24 CG, n = 24 ITT analysis used for primary outcome: NR Inclusion: Men aged 45–65 y, type 2 DM, and symptoms of mild androgen deficiency or ED; in a stable relationship; waist-hip ratio of 0.9 or greater; low testosterone levels (total testosterone < 15.1 nmol/l) Exclusion: concurrent dx other than DM, or surgical intervention likely to impair sexual function, amputation or chronic renal failure, ACE inhibitors' use, hx of alcoholism, prostate enlargement or abnormalities | Age, mean (sd): 58 (5) y Race (%): NR Co-morbidities, (%): peripheral or autonomic neuropathy or retinopathy (50%), CHD (17%), nephropathy (33%) Blood glucose, mean (sd): 10 (2) HbA1C Previous ED treatment: NR BMI, mean (sd): 31 (5) kg/m^2^ Smoking status: NR Body weight: 94 (19) vs. 95 (20) kg | Concomitant medications: oral hypoglycaemic agents in 62.5% (metformin in 25%, metformin + sulphonylurea in 37.5%), insulin mono therapy 12.5%, hypoglycaemic agents + insulin 25% (metformin in 12.5%, sulphonylurea in 12.5%); ACE inhibitors in 35% Duration of ED: NR Underlying disease: diabetes, andropause Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: Mean duration DM = 6 (1–18) y | IG: Testosterone- oral CG: No treatment IG: Dose: 120 mg/d Duration: 3 mo Frequency: twice (80 and 40 mg)/d Compliance: NR CG: Dose: NA Duration: as IG Frequency: NA Compliance: NR Run In period: NR Wash out period: NR F/u duration: 3 mo | Primary outcome results: IG vs. CG, mean (sd) IIEF (abridged 5-item version) score at Baseline: 2 (0.7) vs. 2.5 (0.8) 3 mo: 1.1 (0.9) vs. 2 (0.9), p < 0.05 SBP (mmHg), mean (sd): Baseline: 122 (8) vs. 120 (8); Post tx: 120 (10) vs. 122 (8) mmHg DBP (mmHg), mean (sd): Baseline: 80 (4) vs. 76 (6) Post tx: 82 (4) vs. 76 (6) mmHg Total serum T (nmol/l), mean (sd): Baseline: 9.6 (2.3) vs. 10.8 (3) Post tx (10 hr post last drug administration): 15.5 (3.4) vs. 11.2 (3.2) Other outcomes assessed: body weight, BMI reduction (evident in IG), fasting blood glucose level (sign drop in IG); serum triglyceride levels (drop in both grps); symptoms of androgen deficiency (nervousness, weakness, insomnia, libido) Withdrawals/drop-outs/loss to f/u: NR WDAE: 0 TAE: 0 SAE: 0 Ascertainment of outcomes assessed: IIEF-5; SD by 4 point scale (0–3) questionnaires
Boyanov (2003) ^228^ Funding source: NR | N screened = NR N randomized = 48 (Open-label trial) IG, n = 24 CG, n = 24 ITT analysis used for primary outcome: NR Inclusion: Men aged 45–65 y with DM type 2 and symptoms of mild androgen deficiency or ED, married or living in a stable relationship with a female sexual partner for 6 mo or longer, waist-hip ratio of 0.9 or more, T levels below the normal range of adults or in the lower third of this range (total T < 15.1 nmol/l) Exclusion: concurrent dx other than DM or surgical intervention likely to impair sexual function, amputation or chronic renal failure, ACE inhibitors' use, hx of alcoholism, prostate enlargement or abnormalities | Age, mean (sd): 58 (5) y Race (%): NR Co-morbidities: peripheral or autonomic neuropathy or retinopathy (50%), CHD (16.7%), nephropathy (33%) Blood glucose, mean (sd): 10 (2) HbA1C Previous ED treatment: NR BMI, mean (sd): 31 (5) kg/m^2^ Smoking status: NR Body weight, mean (sd): 94 (19) vs. 95 (20) kg | Concomitant medications: insulin therapy (12.5%), hypoglycaemic agents (25%), or ACE inhibitors only Duration of ED: NR Underlying disease: DM (mean duration = 6, range1–18 y), andropause Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: Testosterone- oral CG: No treatment IG: Testosterone (oral) Dose: 120 mg/d Duration: 3 mo Frequency: twice (80 and 40 mg)/d Compliance: NR CG: No treatment Dose: NA Duration: as IG Frequency: NA Compliance: NR Run In period: NR Wash out period: NR F/u duration: 3 mo | Primary outcome results: IG vs. CG, mean (sd): IIEF (abridged 5-item version) score at baseline: 2 (0.7) vs. 2.5 (0.8) 3 mo: 1.1 (0.9) vs. 2 (0.9), p < 0.05 SBP (mmHg): Baseline: 122 (8) vs. 120 (8) 3 mo: 120 (10) vs. 122 (8) DBP (mmHg): Baseline: 80 (4) vs. 76 (6) 3 mo: 82 (4) vs. 76 (6) Total T (nmol/L): Baseline: 9.6 (2.3) vs. 10.8 (3) 3 mo: 15.5 (3.4) vs. 11 (3.2) Other outcomes assessed: insomnia, nervousness, weakness, libido, fasting blood glucose, total cholesterol, high-density lipoprotein (HDL)-cholesterol, low-density lipoprotein (LDL)-cholesterol, triglyceride Withdrawals/drop-outs/loss to f/u: NR WDAE: 0 TAE: 0 SAE: 0 Ascertainment of outcomes assessed: IIEF questionnaires, anthropometrical measures, routine blood biochemistry
Cavallini (2004) ^229^ Funding source: NR | N screened = 224 N randomized = 150 (n/ grp is not reported) N (total) completed = 130 IG1, n = 40 IG2, n = 45 CG, n = 45 ITT analysis used for primary outcome: No Inclusion: pts > 60 yrs with symptoms of androgen decline: ▾ libido and erectile quality, depressed mood, irritability, fatigue, and free testosterone < 6 pg/ml Exclusion: lower urinary tract obstructive symptoms, prostate volume > 20 cm 3, ▴ PSA level and/or prostate cancer, alcohol or cigarette consumption, < 6 mo after major surgery or MI, diabetes, untreated hypertension, CVD, neoplasm, ongoing psychological/pharmacological or antineoplastic therapy, ▴ PRL serum levels | Age, mean (range): 66 (60–74) y Co-morbidities: NR Previous ED treatment: NR Body weight: NR Other: testosterone (nmol/l) =10 (2) vs. 11 (2) vs. 11 (2) | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: Testosterone undecanoate -oral IG2: Propionyl-L carnitine + acetyl -L-carnitine(carnitine)- IM CG: Placebo (starch)- oral IG1: Dose: 160 mg/d Duration: 6 mo Frequency: daily Compliance: NR IG2: Dose: 2 g/d Duration: 6 mo Frequency: daily Compliance: NR CG: Dose: 500 mg starch tablet Duration: 6 mo Frequency: daily Compliance: NR Run In period: NR Wash out period: NR F/u duration: at 6 mo (immediately post tx), and 6 mo post end tx (12 mo) | Primary outcome results: IIEF-15 EF, median (range): Baseline= 8 (5–22); 6 mo= 16 (6–29) vs. 24 (8–29) vs. 9 (6–22), p < 0.01; 12 mo= 8 (5–22) Sexual intercourse satisfaction, median (range): baseline= 4 (2–7); 6 mo= 5 (3–10) vs. 6 (3–10) vs. 4 (3–5) PSA, mean (sd): 2 (1) vs. 2 (1) vs. 2 (1) ng/mL (not different from baseline) NPT (3-night full erection duration): baseline= 83 (19) min; 6 mo =120 (26) vs. 158 (28) vs. 88 (23) min; 12 mo 87 (21) vs. 85 (23) vs. 87 (19) Free T (pg/mL) mean (sd): baseline= </=5 (0.9); 6 mo= 23 (4) vs. 5 (1) vs. 4 (0.7); 12 mo= 10 (2) vs. 11 (2) vs. 10 (2), (IG1 vs. IG2, p=> 0.05) Other outcomes assessed: PSA, prostate volume, PSV, Total T, LH, EDV, resistive index (RI), IIEF domains of orgasm, SD, sexual well-being Withdrawals/drop-outs/loss to f/u, n (%): 20 (13) WDAE: 0 TAE, n (%): 3 (2); 2 mild epigastralgia, 1 mild headache SAE: NR Ascertainment of outcomes assessed: IIEF (Q15); nocturnal penile tumescence (NPT) by RigiScan
Clopper (1993) ^230^ Funding source: USPHS grant, NIH General Clinical Research Centre Grant, and fund from the Children's Growth Foundation | N screened = 11 N randomized = 9 (Blind crossover design) IG1, n = 3 IG2, n = 3 CG, n = 3 ITT analysis used for primary outcome: NR Inclusion: Hypogonadal male subjects at least 15 y, and being treated for hypopituitarism. Exclusion: Non-hypogonadal men and younger than 15 yrs. | Age, mean (range); 18 (16.2–20.9) y Race: NR Co-morbidities: NR Previous ED treatment; n (%): 7 (78), T enanthate tx (50–400 mg/mo) Smoking status: NR Body weight mean (range): 66 (51–113) kg | Concomitant medications: None Duration of ED: NR Underlying disease: Previous pituitary tumours. Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: Testosterone IM IG2: Gonadotropin IM CG: Placebo IM IG1: Dose: 2000 units human chorionic gonadotropin (1cc IM) Duration: 6mo Frequency: 1/2 wks (5 injections of saline to maitain 3 times/ wk) Compliance: 100 % IG2: Dose: 1cc IM injection Duration: 6 mo Frequency: 3 times/wk Compliance: 100% CG: Dose: 1cc IM injection Duration: 2 mo Frequency: 3 × per wk Compliance (%): (100) Run In period: 4 wks Wash out period: min 4 wks (mean 6.7wks) F/u duration (on and off treatment): NR Other: Min of 6mo on either treatment and then placebo for 2mo | Primary outcome results: Weekly frequency, mean (sd): Erection, wkly frequency: baseline =4 (3); Post tx: 8 (6) vs. 8 (7) vs. 5 (3) % of sleep with erection: Baseline = 0.3 (0.1); Post tx: 0.6 (0.2) vs. 0.6 (0.2) vs. 0.4 (0.2) % Time erection with max circumference: baseline= 0.6 (0.04); Post tx: 0.3 (0.1) vs. 0.2 (0.2) vs. 0.1 (0.05) # of erections per night: Baseline =7 (2); Post tx: 6 (2) vs. 6 (3) vs. 7 (3) Coitus, mean #/ wk (sd): Baseline =1.4 (1); Post tx: 0.9 (1) vs. 0.8 (1) Plasma T (ng/dl): baseline =23 (43); Post tx: 921 (383) vs. 1028 (773) vs. 34 (30) Urinary LH: 5265 (3294) vs. 8017 (10232) vs. 20047 (11864) vs. 8105 (6401) Other outcomes assessed: ejaculation, masturbation Withdrawals/drop-outs/loss to f/u: None WDAE: None TAE: NR SAE: NR Ascertainment of outcomes assessed: Self reports of sexual behaviour (7-point Likert scale)
Gomaa (2001) ^231^ Funding source: NR | N screened = NR N randomized = 42 (crossover-two phases) IG1/IG2 n = 42 ITT analysis used for primary outcome: NR Inclusion: ▾ in libido, Serum total testosterone near lower end of normal [defined as > 250 ng/dl] 200 – 350 ng/dl selected Exclusion: hx prostate dx, including: prostate cancer, recurrent prostatitis, benign hyperplasia or prostatic hypertrophy. Cavernous fibrosis, anatomical deformation of penis, glaucoma, hypotension or cardiac arrhythmia | Age, mean (range): 54 (41–67) y Race (%): NR Co-morbidities: NR Previous ED treatment: NR Smoking status: all non-smoker Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED, n (%): 19 (90) Physiologic ED, n: Vasculogenic: 18 Neurogenic; 5 Mixed ED: 0 | IG1: Co-dergocrine mesylate 0.06% + isosorbide dinitrate 0.5% + topical T 0.8% (polypharmacy cream) IG2: topical T 0.8% IG1: Dose: 2 g in 2 ×15 divided doses Duration: 1 mo Frequency: once/d applied to shaft at bedtime or 15 min before sexual activity Compliance: 100% IG2: Dose: 2 g in 2 × 15 divided doses Duration: 1 mo Frequency: once/d Compliance: 100% Run In period: If on IC vasodilator or androgen preparation: 6 wks- 2 wks post Papaverine test Wash out period: 1 wk F/u duration: 2 mo | Primary outcome results: Full erection with intercourse, mean n (%): 6 (3) vs. 4 (2), (p<0.05) Erectile response (30 d), n of pts with at least 2 positive response/mo (%): Full: 28 (66) vs. 13 (31); Partial: 2 (5) vs. 2 (5); Tumescence: 3 (7) vs. 0 No response: 9 (21) vs. 27 (64) Other outcomes assessed: Serum T level ▴ in all compared to onset (p<0.05); penile arterial flow ▴ IG1 vs. IG2, p<0.001; SPV: IG1 vs. IG2, p <0.001;quality of life (QOL) in favour of T-gel Withdrawals/drop-outs/loss to f/u: 0 WDAE: 0 TAE, n (%): 5 (12), all in IG1 with mild transient headache SAE: 0 Ascertainment of outcomes assessed: Questionnaire for SD (analogue), frequency of activity, erectile response (full, partial, tumescence, no response)
Haren (2005) ^232^ Funding source: Organon Pty Ltd | N screened = NR N randomized = 76 IG, n = 39 CG, n = 37 ITT analysis used for primary outcome: Y Inclusion: healthy men, at least 2 symptoms on the St-Louis University ADAM questionnaire, a free testosterone index (FTI) between 0.3 and 0.5 total T>8 nmol/l. Exclusion: prostate cancer or a PSA > 5 ng/ml, International Prostate Symptoms Score (IPSS) > 20, abnormal prostate on digital rectal examination, hx of testicular, liver, or renal dx, DM, cardiac failure, a score of greater than 15 on the Geriatric Depression Scale, sign. joint pain, prior use of androgen, bisphosphonates, oral, IV or intraarticular glucocorticoid within the preceding 6 mos. or an haematocrit greater than 50%. | Age, mean (sd), range: 68.5 (6), 60–86 y Co-morbidities: NR Previous ED treatment: NR BMI (kg/m^2^): NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: Testosterone -oral CG: Placebo- oral IG: Dose: 80 mg TU (Andriol) Duration: 12 mo Frequency: twice/d Compliance: 69.7% took 90% or more of tablets; 27% took between 51–89% of the assigned tablets CG: Dose: placebo Duration: 12 mo. Frequency: twice/d Compliance: 80% took 90% or more of tablets; 20% took between 51–89% of the assigned tablets Run In period: NR Wash out period: NR F/u duration: 12 mo | Primary outcome results: Androgen deficiency (ADAM) questionnaire (% ‘yes’ response): Report of less strong erections: baseline: 95 vs. 95 12 mo: 86 vs. 93 (p>0.05) ADAM questionnaire when calculated bioavailable T (cBT) < 3.1 nmol/l): Report of less strong erections: Baseline: 100 vs. 95 12 mo: 89 vs.94 (p>0.05). Other outcomes assessed: improvement in libido, energy, strength, enjoyment of life, mood, ability to play sports, and work performance Withdrawals/drop-outs/loss to f/u: 6 vs. 12 WDAE: NR TAE: NR SAE: 0 Ascertainment of outcomes assessed: Androgen deficiency (ADAM) questionnaire: (ED: are your erections less strong?); cBT: calculated from TT
Kunelius (2002) ^233^ Funding source: Laboratories Besins Iscovesco supplied the study drug Funding: Sigrid Juselius Foundation and the Academy of Finland | N screened = 178 N randomized = 120 IG, n = 60 CG, n = 60 ITT analysis for primary outcome: NR Inclusion: Nocturnal penile tumescence ≤ 1 / wk; One of the following andropause symptoms: ▾libido, ED, urinary dx, asthenia or a depressive mood; total serum T ≤ 15 nmol/L and/or serum SHBG > 30 nmol/l Exclusion: abnormal liver parameters; PSA > 10 μg/l; prostate weight > 100 g; acute prostatitis, abnormal prostate in clinical or ultrasonographic exam; prostactectomy/transurethral resection of the prostate; sign cardiovascular dx; abnormal lipid profile; alcohol abuse; uncured cancer, neurological impotence, psychiatric dx; taking hormones or drugs affecting sexual function (other criteria could be found in the full report) | Age, mean (sd): 58.4 (5.3, range 50 70 y) y Co-morbidities: NR Previous ED treatment, n: 5 vs. 9 (not specified) BMI, mean (sd): 26 (2) vs. 26 (3) kg/m^2,^(p>0.05) Smoking status: NR Body weight: 79.5 (9) vs. 81 (9.7) kg Other, n: Testosterone ≤ 15 nmol/L: 51 Testosterone <9 nmol/L: 5 SHBG > 30 nmol/L: 111 SHBG >62 nmol/L: 22 Free Androgen Index: 35.5 ± 10.8 | Concomitant medications: NR Duration of ED (yr): NR Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: Dihydrotestosterone (DHT) gel Transdermal CG: Placebo Transdermal gel IG: Dose: 125 mg/ d for 30 d, titrated up to 250 mg/day according to DHT levels Duration: 6 mo Frequency: Once/d Compliance: 100% CG: Dose: placebo (NA) Duration: 6 mo Frequency: Once daily Compliance: 100% Run In period: NR Wash out period: NR F/u duration: 6 mo | Primary outcome results: IG vs. CG, mean (sd): Ability to maintain erection during intercourse: 3.2 (1.4) vs. 3 (1.6), p< 0.04 Serum T (nmol/l): 6 (4) vs. 15 (5) p<0.001) Other outcomes assessed: SHBG: 39 (13) vs. 43 (17) nmol/l p=0.003 FSH: 4 (4) vs. 16 (5) IU/l, p<0.001 LH: 2 (2) vs. 5 (3) IU/l, p<0.001;DHT: 8 (5) vs. 2 (0.7) nmol/l, p<0.001 Withdrawals/drop-outs/loss to f/u, n (%): 6 (5), All in IG1 WDAE: 0 TAE: Mild headache: 3 vs. 2 Skin irritation:0 vs. 0 Hair growth on shoulder/arm: 1 vs. 0 Mild depression: 2 vs. 2 SAE: 0 Ascertainment of outcomes assessed: General well being questionnaire: A modified Psychological General Well-Being scale (13 items) and 12 items from IIEF
McNicholas (2002) ^234^ Funding source: Auxilium UK Ltd. | N screened = NR N randomized = 208 IG1, n = 68 IG2, n = 72 IG3, n = 68 CG, n = NA ITT analysis used for primary outcome: No Inclusion: ageing men with low serum T (≤ 10.4 nmol/l) and associated signs and symptoms of hypogonadism Exclusion: NR | Age, mean (sd): 58 (10) y; range: 31–80 y Co-morbidities: NR Previous ED treatment: NR BMI, mean (sd): 28 (4) kg/m^2^ Smoking status: NR Body weight mean (sd): 86 (12) vs. 88 (12) vs. 89 (12) kg Other: Testosterone, (mean, SD): all pts 8 (2.3) nmol/l PSA, mean (sd): all pts 1.3 (1.3) ng/mL | Concomitant medications: NR Duration of ED: NR Underlying disease, n: Primary hypogonadism: 6 vs. 10 vs. 4; Secondary hypogonadism: 62 vs. 62 vs. 64 (aging (%): 60 vs. 56 vs. 59; Normogonadotrophic (%): 13 vs. 22 vs. 25) Psychogenic ED: 0 Physiologic ED: 100% Mixed ED: NR | IG1: Testim, testosterone gel IG2: Testim, testosterone gel IG3: Andropatch, patch (open label) IG1: Dose: 50 mg Duration:90 d Frequency: daily Compliance: 97% IG2: Dose: 100 mg Duration: 90 d Frequency: daily Compliance: 97% IG3: Dose: 2 × 2.5 mg Duration: 90 d Frequency: daily Compliance: 96% Run In period: NR Wash out period: NR F/u duration: NA | Primary outcome results: IG1 vs. IG2 vs. IG3, change from baseline, mean (sd): Sexual function: Spontaneous erections, mean /wk: 0.6 (1.4) vs. 0.5 (1.4) vs. 0.3 (1.2) Motivation, mean/wk: 0.4 (1.2) vs. 0.4 (1.3) vs. 0.5 (1.4) Desire mean/wk: 0.8 (1.0) vs. 0.7 (1.4) vs. 0.5 (1.2) Performance mean/wk: 0.3 (1) vs. 0.4 (0.9) vs. 0.3 (1) Other outcomes assessed: serum free T; C-average T; C-average dihydrotestosterone Withdrawals/drop-outs/loss to f/u: NR WDAE, (%): 4 vs. 0 vs. 13 most related to skin irritation TAE: incidence of 1 or more AE= 35% vs. 29% vs. 63%, erythema, irritation, and reactions at application site SAE: 0 Ascertainment of outcomes assessed: sexual function and mood questionnaires for hypogonadal men physical exam, scoring system for skin irritation
Merza (2005) ^235^ Funding source: Ferring Pharmaceuticals Ltd. | N screened = NR N randomized = 39(the trial was followed by a 6 mo open label phase) IG, n = 20 CG, n = 19 ITT analysis used for primary outcome: NR (analysed for 20 vs.18) Inclusion: men 40 or older, with borderline hypogonadism defined as T level <10 nmol/L or a free androgen index <30%), presenting with sexual dysfunction Exclusion: prostate or breast cancer, prostatic hypertrophy, raised serum PSA (>2.5 μg); uncontrolled hypertension; DM; uncontrolled cardiac disease; renal failure; liver disease; polycythaemia; hx of aggressive behaviour, alcohol or drug abuse; anticoagulant tx or testosterone replacement tx | Age, mean (sd): 62 (9.7), range 40–77.4 y Race: NR Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): NR Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG: Testosterone patch CG: Placebo IG: Dose: 328 mg patch delivering 5 mg/d Duration: 6 mo Frequency: one/d (in the morning) Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: NR Wash out period: NA F/u duration: 6 mo | Primary outcome results: Not measured MED QoL score, mean (sd): Baseline: 61.4 (17.5) vs. 54.2 (15.9) 6 mo: 61.8 (22.1) vs. 43.6 (4.21), p=0.017 GWBI score, mean (sd): Baseline: 75.8 (13.4) vs. 63.5(16) 6 mo: 75.8 (13) vs. 60.8 (11) Other outcomes assessed: Hormones; bone turnover markers, bone mineral density, fat mass, lean mass, laboratory safety measures Withdrawals/drop-outs/loss to f/u, n (%): 0 vs. 1 (5.3) WDAE, n (%): 0 vs. 1 (5.3) due to angina TAE, n (%): NR SAE, n (%): NR Ascertainment of outcomes assessed: laboratory testing for body composition, markers of bone turnover, hormone measurements; QoL measured by questionnaires (the Male Erectile Dysfunction Quality of Life questionnaire, MEDQoL; and General Well-Being Index, GWBI) scored 0–100
Padma-Nathan (2006) ^223^ Funding source: NexMed (study drug supply); co-author a paid consultant of NexMed | N screened = N randomized = 1732 IG1, n = 434 IG2, n = 430 IG3, n = 434 CG, n = 434 ITT analysis used for primary outcome: yes (pts with at least one study medication) Inclusion: men at least 21 y, in a stable relationship, and hx of ED of at least 3 mo in duration Exclusion: ED due to untreated endocrine disease or sing penile pathology (i.e. penile fibrosis, Peyronie disease) | Age, mean (se): 61 (0.47) y Race: White 86%; Black 8.3%; Hispanic 3.9%; other 1.8% Co-morbidities, n (%): DM 305 (17.6); cardiac 503 (29); prostatectomy 220 (12.7) slightly higher in IG1; hypertension 783 (45.2) Previous ED treatment: sildenafil [failures 352 (18.8)] Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): NR Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG1-3: Alprostadil topical cream CG: Placebo cream IG1-3: Dose: IG1=100 μg, IG2 = 200 μg, IG3=300 μg Duration: 12 wks Frequency: up to 24 applications (2/wk) Compliance: NR CG: Dose: Duration: 12 wks Frequency: as IG Compliance: NR Run In period: 4 wks drug free Wash out period: F/u duration: 16 wks | Primary outcome results: IIEF-EF, LS mean change from baseline (se): IG: 1.6 (0.34) vs. 2.5 (0.34) vs. 2.4 (0.34), CG -0.7 (0.34) SEP, LS mean % change form baseline (se): SEP-2: IG 2.9 (1.63) vs. 5.1 (1.65) vs. 7.2 (1.65), CG -4.5 (1.65) SEP-3: IG 7.0 (1.61) vs. 13.8 (1.63) vs. 9.1 (1.63), CG 0.4 (1.64) GAQ, % improved: IG 40% vs. 47% vs. 52%, CG 20% Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): WDAE, n (%): 46 (2.7) TAE, n (%): 198 (45.6) vs. 267 (62.1) vs. 292 (67.3) vs. CG 54 (12.4) Body as whole: IG 5 (1.2) vs. 1 (0.2) vs. 0 CG 1 (0.2); nervous system IG 5 (1.2) vs. 7 (1.6) vs. 11 (1.2), CG 1 (0.2) Skin rash: IG 2 (0.5) vs. 5 (1.2) vs. 2 (0.5) CG 1 (0.2); urogenital system: IG 186 (42.9) vs. 254 (59.1) vs. 279 (64.9) CG 51 (10.6) SAE, n (%): IG 0, CG 1 (0.2) died due to cardiac arrest Ascertainment of outcomes assessed: IIEF-EF; SEP; GAQ
Rabkin (2000) ^236^ Funding source: NR | N screened = 104 N randomized = 74 IG, n = 39 CG, n = 35 ITT analysis used for primary outcome: N Inclusion: men 18 yrs, HIV seropositive (CD4 cell counts less than 0.4 × 10^9^/L), clinically deficient or low-normal serum T < 17.4 nmol/L (except acquired immunodeficiency syndrome with severe fatigue, upper limit 22.6 nmol/L), sexual dysfunction, at least one associated hypogonadal mood symptom, receiving medical care for HIV illness Exclusion: substance use in past 6 mo, psychotic symptoms, sign suicidal risk, sign cognitive impairment, unstable medical condition including new onset of an opportunistic infection in the past mo, symptomatic benign prostate hyperplasia, current or anticipated use of a new antiretroviral medication within 4 wks, or use of anabolic steroids in past mo | Age, mean (sd): 38 (7.3) vs. 40 (9) y Race, n (%): non-white 18 (47) vs. 18 (56) Co-morbidities: NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: T level (nmol/L), mean (sd): 13 (5) vs. 3 (4); n=14 (20) baseline T levels below 10.4 nmol/l (hypogonadal) | Concomitant medications: NR Duration of ED: NR Underlying disease: HIV-positive with hypogonadal symptoms and sexual dysfunction 74 (100%) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: testosterone cypionate,- IM CG: placebo- IM IG: Dose: initial 200 mg, ▴ to 400 mg Duration: 6 wks Frequency: bi-weekly Compliance: NR CG: Dose: initial 200 mg, ▴ to 400 mg Duration: 6 wks Frequency: bi-weekly Compliance: NR Run In period: NA Wash out period: NR F/u duration: 6 wks + 12 wks (maintenance for responders) = 18 wks | Primary outcome results: CGI, sexual interest, EF& mood, mean (%): 28(74) vs. 6 (19) = P < 0.001 CGI, improved/much improved among completers, n (%): 20 (63) vs. 4 (20); not different between hypogonadal men and men with normal T levels Reynolds sexual function scale, mean (SE): morning erections 5.4 (0.4) vs. 4 (0.4), P=0.008 Total serum T (nmol/L), mean change from baseline: IG responders=non responders 35 (15) vs. CG responders = 11.4 (7.4), non responders= 2 (6.4), p=0.005 Other outcomes assessed: mood, depression, anxiety, quality of life, laboratory measures Withdrawals/drop-outs/loss to f/u: 4 (vs.3) WDAE: NR TAE, n (%): Pts with 1 or more AE: 16 (41) vs. 7 (20), p=0.05; AE include ▾ ejaculation; testicular atrophy; irritability; acne (21% of pts vs. 0); tension; bossiness; hair loss SAE: 2 (IG) hospitalized due to HIV Ascertainment of outcomes assessed: Clinical global impressions scale ratings (CGI): 7-point scale Reynolds sexual function scale (self report10-point); Structured assessment of tx emergent AEs
Raul (1997) ^237^ Funding source: National Institute on Aging | N screened = 40 N randomized = 18 (cross over design) IG/ CG, n = 18 ITT analysis used for primary outcome: NR Inclusion: men 45–74 yr, with primary diagnosis of ED or hypo active SD, (ED: inability to achieve and maintain vaginal penetration until orgasm on at least 50% of the attempts during the preceding 6 mo; Hypoactive SD: SD for any sexual activity of less than twice per mo during the preceding 6 mo) Exclusion: evidence of medical disorder, intake of drug especially neurological, vascular or endocrine action drugs; alcohol or other substances of abuse; presence of major psychopathology; obesity (> 20% above ideal body weight) | Age, median (range): Median 60 (46–67) y Race (%): Caucasian 97; NR 3 Co-morbidities: NR Previous ED treatment NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED, median (range): 4 y (6 mo- 12 yr) Underlying disease: NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG: Testosterone IM (enanthate) CG: placebo (sesame oil vehlicle) IG1: Dose: 200 mg Duration: 6 wks Frequency: twice/ wk Compliance: NR CG: Dose: NR (0) Duration: 6 wks Frequency: as IG Compliance: NR Run In period: NR Wash out period: 4 wks F/u duration: 16 wks | Primary outcome results: Frequency (times/ wk), median (range): SD 6 (0–7) vs. 4 (0–7) Masturbation 1 (0–2) vs. 0.16 (0–2); Sex with partner 1 (0–2) vs. 0.54 (0–2.7) Morning erections 1.25 (0–7) vs. 0.67 (0–7 Degree of erection (score 1–6): Masturbation: 6 (3–6) vs. 6 (1–6) Sex with partner: 6 (4–6) vs. 6 (1–6) T (ng/ml), mean (sd): Baseline: 412 (48) vs. 481 (205) Period 1: 318 (66) vs. 455 (143) Period 2: 420 (87) vs. 397 (73) Other outcomes assessed: Sexual behaviour and mood Plasma T, LH (sign. compare to baseline in IG), dihydrostestosterone Withdrawals/drop-outs/loss to f/u: n=6 (n=1 excluded from analysis due to diagnosis of primary hypoactive SD) WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: Psychological assessment: 1) ED by brief sexual function questionnaire (19 items), 2) mood assessment by POMS (65 items), 3) distress by SCI-90-R (90 items each on a 5-point scale
Rochira (2006) ^238^ Funding source: Ministero dell'Università e della Ricera Scientifica | N screened = NR N randomized = 24 (Italy) Grp 1 Hypogonadal not treated IG1/CG1, n = 12 Grp 2 Hypogonadal treated IG2/CG2, n = 12 ITT analysis used for primary outcome: NR Inclusion: hypogonadal men (serum T level of 20 ng/dL used as cut-off); pts included 14 pts who had been withdrawn from T replacement tx for at least 3 mo and 10 hypogonadal pts at 1^st^ diagnosis Exclusion: NR Note: n=24 healthy subjects were recruited as control grp; data not shown in this table | Age, mean (sd): 34.54 (11.5) y Race: NR Co-morbidities, n (%): hypogonadal 24(100) including Klinefelter syndrome 7 (29) Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): hypogonadalism Psychogenic ED, n (%): NR Physiologic ED, n (%): 100% Mixed ED, n (%): NR | IG1/2: Sildenafil CG: Placebo IG1/2: Dose: 50 mg Duration: 3 nights Frequency: 1 hr before bedtime; on 2^nd^ (IG1) or 3^rd^ (IG2) night post nocturnal monitoring Compliance: 100% CG1–2: Dose: NA Duration: as IG Frequency: as IG Compliance: 100% Run In period: 1 night (adaptation) Wash out period: NR F/u duration: Note: T tx started for grp1 no longer than 20 d post enrolment (250 IM/ 21d); T tx period was a non-randomized open label 6 mo study for all hypogonadal men; NR in this evidence table | Primary outcome results: IG vs. CG, mean (sd): N of valid erections: Grp 1: 2.71 (0.18) vs. 0.76 (0.22) Grp 2: 4.29 (0.24) vs. 2.79 (0.27) Duration of rigidity >70% (min): Grp 1: 43.59 (5.14) vs. 10.57 (3.83) Grp 2: 105 (13.02) vs. 52.02 (8.75) Max rigidity, %: Grp 1: 79.21 (3.44) vs. 60.83 (3.83) Grp 2: 91.75 (1.54) vs. 84 (2.10) Max ▴ of circumference (mm): Grp 1: 33.46 (0.89) vs. 25.79 (1.45) Grp 2: 43.58 (1.31) vs. 40 (1.70) Other outcomes assessed: duration of ▴ of circumference of at least 30 mm (sign more in IG vs. CG) Withdrawals/drop-outs/loss to f/u, n (%): 0 WDAE, n (%): 0 TAE, n (%): 0 SAE, n (%): 0 Ascertainment of outcomes assessed: RigiScan monitoring for nocturnal penile tumescence measures
Seftel (2004) ^239^ Companion study ^240^ Funding source: Auxilium Pharmaceuticals Inc. | N screened = NR N randomized = 406 IG1, n = 99 (double blind) IG2, n = 106 (double blind) IG3, n = 102 (open label) CG, n = 99 ITT analysis used for primary outcome: Yes Inclusion: hypogonadal men 20–80 (secondary to aging and also normogonadotrophic) with morning T level up to 300 ng/dL (10.4 nmol/L), with one or more symptoms of low testosterone (fatigue, reduced libido, reduced sexual functioning, ▾ muscle mass) Exclusion: NR Note: pts with T levels of > 300 were also randomized as protocol deviations (n=15) *n of pts evaluated for frequency of intercourse differs from those evaluated for SD & night time erections because requirement for steady sexual partner was not a requirement for study entry* | Age, mean: 58 y Race (%): NR Co-morbidities: NR Previous ED treatment: NR BMI, mean: all pts 30 kg/m^2^ Smoking status: NR Body weight, mean range: 95–99 kg Other: Testosterone (nmol/L) all pts: 10.4–34.7; Mean (sd): 234 (57) vs. 232 (62) vs. 239 (69) vs. 229 (80) ng/dL Sexual function (likert scale), mean (sd) Baseline: 2 (1) vs. 3 (1) vs. 2 (1) vs. 2 (1) | Concomitant medications: NR Duration of ED: NR Underlying disease: primary 6%, or secondary 94% (58–71% due to aging 19–32% due to normogonadotrophic) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: Testosterone gel IG2: Testosterone gel IG3: Testosterone patch CG: placebo gel IG1: Dose: 50 mg (n= 43 titrate ▴ at 60 d) Duration: 90 d Frequency: daily Compliance: 100% IG2: Dose: 100 mg (n=4 titrated ▾at 60 d) Duration: 90 d Frequency: daily Compliance: 100% IG3: Dose: 2 × 12.2 mg patches Duration: 90 d Frequency: daily Compliance: 100% CG: Dose: NA Duration: 90 d Frequency: daily Compliance: 100% Run In period: 7 d Wash out period: NR F/u duration: 30 and 90 d | Primary outcome results: IG1 vs. IG2 vs. IG3 vs. CG (at 90 d) ▴ SD from baseline (likert scale, mean daily score): 0.5 vs. 1 vs. 0.6 vs. 0.5 Pts with ▴ # of night time erections/ wk (%): 30 vs. 51 vs. 40 vs. 26 (at 30 d; no sign. difference at 90 d) Pts with ▴ in intercourse from baseline (%): 6 vs. 36 vs. 13 vs. 28 % of full erection: no data (not sign) C-average Serum T, mean (sd): 218 (74) vs. 315 (112) vs. 373 (145) vs. 487 (213) Other outcomes assessed: change in # of d/wk with nighttime or d time erections, former correlated with serum T levels at 30, and 90 d; mood; PSA levels Withdrawals/drop-outs/loss to f/u, n (%): 21 (5) due to AE WDAE, n (%): all 21 (5%); 1 vs. 5 vs. 15 vs. 0 TAE: NR (AE included: in IG2 vertigo; CA; depression with suicidal intent; UTI/pneumonia; hypertension; 15 in IG3 due to local dermal site reactions) SAE: NR Ascertainment of outcomes assessed: Self report daily diary, SD by Likert scale (0–7)
Seidman (2006) ^241^ Funding source: NIH (partnership for Gender-Specific Medicine) | N screened = NR N randomized = 30 IG, n = NR CG, n = NR ITT analysis used for primary outcome: NR Inclusion: men 35 or older with MDD, and low serum T (350 ng/dl or less) Exclusion: bipolar illness, schizophrenia, substance abuse or dependence (current or within last yr); active suicidal ideation; or acute severe or unstable medical illness; men age over 50 with PSA level of 4.0 or higher or an abnormal digital rectal exam were excluded | Age, mean (sd): 52 (8) y Race: NR Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: T level, mean (sd) ng/dl HAMD score 21 (8) | Concomitant medications, n (%): Duration of ED: NR Underlying disease, n (%): MDD in all Psychogenic ED, n (%): 100% Physiologic ED, n (%): NR Mixed ED, n (%): NR Other: duration of current MDD, median 26 mo, range 4–120 mo | IG: T enanthate IM injection CG: placebo injection (sesame oil) IG: Dose: 200 mg Duration: 6 wks Frequency: once/wk Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: NR Wash out period: NA F/u duration: 6 wks | Primary outcome results: DSPS-M section II, mean (sd): -Full erection on awakening: Baseline: 1.15 (1.82) vs. 1.47 (1.66) Post tx: 2.08 (2.29) vs. 2.18 (2.0) -Full erection on fantasy/ daydream: baseline 1.15 (1.72) vs. 1.88 (1.86) Post tx 1.78 (2.16) vs. 1.71 (1.83) -Full erection on masturbation: Baseline 1.08 (1.66) vs. 1.59 (1.91) Post tx 1.69 (2.25) vs. 1.71 (1.90) -Full erection during sexual activity: Baseline 1.54 (1.94) vs. 1.18 (1.78) Post tx 1.77 (2.17) vs. 1.53 (1.62) -A satisfying orgasm: Baseline 1.92 (1.44) vs. 1.82 (1.81) Post tx 2.31 (2.06) vs. 2.06(1.44) -Serum T level, mean: Baseline 262.5 (8) Post tx 981.3 vs. 297.7 ng/dl Other outcomes assessed: no association for changes in T level and depressive symptoms Withdrawals/drop-outs/loss to f/u, n (%): 1 (3.3) WDAE, n (%): 1 (3.3) TAE, n (%): NR SAE: 1 MI in CG Ascertainment of outcomes assessed: self reported sexual function; HAMD; DSPS-M section II (scale 0–8, 0=none; 8=4 or more per d)
Shabsigh (2004) ^242^ Funding source: Solvay Pharmaceuticals Inc. | N screened = 354 N randomized = 75 IG, n = 39 (ITT, n=37) CG, n = 36 (ITT, n=33) ITT analysis used for primary outcome: yes Inclusion: men 18–80 y, with ED of 3 mo or longer, in a stable sexual relationship with a female ≥ 6mo, morning serum total T of 400ng/dl or less at screening visits, nonresponders to Sildenafil monotherapy (determined by IIEF) Exclusion: hx of prostate or breast cancer, clinically sign or uncontrolled medical or psychiatric conditions (including DM), neurological dx that cause ED, generalized skin dx that would affect gel absorption, hyperprolactinemia, drug or alcohol abuse, prostate dx with concomitant urine flow rate of less than 12 ml/s | Age, mean (sd): 57 (10), range = 26–73 vs. 59 (9), range = 40–79 y Race, n (%): White 53 (71); Black 7 (9); Asian 2 (3); Hispanic 8 (11) Co-morbidities: NR Previous ED treatment: NR BMI, mean (sd): 32 (5) vs. 31 (6) kg/m^2^ Smoking status, n (%): 4 (11) vs. 6 (18) Body weight: NR | Concomitant medications: NR Duration of ED, n (%): 6–12 mo: 2 (5) vs. 4 (12); > 12 mo: 35 (95), vs. 29 (88) Underlying disease, n (%): DM 7 (19) vs. 4 (12) Hypertension 12 (32) vs. 13 (39); Hpyperlipidemia 10 (27) vs. 4 (12); Prostate dx 5 (14) vs. 1 (3) Psychogenic ED, n (%): 1 (3) vs. 2 (6) Physiologic ED n, (%): 20 (54) vs. 14 (42) Mixed ED, n (%): 16 (43) vs. 17 (52) | IG: Testosterone gel + Sildenafil- oral CG: Placebo gel + Sildenafil -oral IG: Dose: 1% T gel + 100 mg Sildenafil Duration: 12 wks Frequency: gel 1×/day + Sildenafil as indicated Compliance: 100% CG: Dose: 5 g placebo gel + 100 mg Sildenafil Duration: 12 wks Frequency: gel: 1/day + Sildenafil as indicated Compliance: 100 % Run In period: 4 wks Wash out period: NR F/u duration: longer than 12 wks (end point not specified) | Primary outcome results: IIEF- EF domain, mean change from baseline: 4.4 vs. 2.1, p =0.029 IIEF-Q5: IG better than CG, (12 wk, p=0.008, end point p=0.004) Pts who improved at least 1 category from baseline for IIEF-Q3 or 4, n (%): 26 (79) vs. 22 (71) IIEF-Q3–4, n (%) with positive response: 12 wks: 19 (58) vs. 13 (42) Endpoint: 19 (51) vs. 13 (39) Serum T levels ▴ from baseline at 12 wks: IG, p</=0.004; IG vs. CG, p</=0.001 Other outcomes assessed: no correlation between serum T levels and IIEF at endpoint; QoL Withdrawals/drop-outs/loss to f/u, n (%): 7 (19) vs. 5 (14) WEAE, n: 1(3) vs. 0 TAE: 1 vs. 0; detail not reported SAE: 0 Ascertainment of outcomes assessed: IIEF; GAQ
Shamloul (2005) ^243^ Funding source: NR | N screened = 40 N randomized = 40 IG1 (non responders to sildenafil), n = 10 CG1, n = 10 (1) IG2 (partially responders to sildenafil), n = 10 CG2, n = 10 (2) ITT analysis used for primary outcome: NR Inclusion: Men with ED associated with PADAM (partial androgen deficiency in aging men) symptoms. Suffering from ED for at least 6 mo. All patients were married and engaged in regular sexual activity (2 × wk); pts recruited after a sildenafil trial. Exclusion: Patients with prostate hypertrophy, prostate carcinoma and mammary carcinoma. No patients were diabetic or hypertensive | Age, mean (sd); 56 (2.4) y Race: NR Co-morbidities: NR Previous ED treatment: Sildenafil for 2wks BMI, mean (sd): 29 (3.2) kg/m^2^ Smoking status: NR Body weight, mean (sd): 81 (1.4) kg | Concomitant medications: NR Duration of ED: at least 6 mo Underlying disease: None Psychogenic ED: None Physiologic ED: None Mixed ED: None | IG1: Sildenafil + TRT (Testosterone underacanoate- oral) CG1: TRT IG2: Sildenafil + TRT CG2: TRT IG1/IG2: Dose: 50 or 100 mg + 120 mg Duration: 2 mo Frequency: 3 capsules/d Compliance: all CG1/CG2: Dose: 120 mg Duration: 2 mo Frequency: as IG Compliance: all Run In period: 2 wks Wash out period: None F/u duration: 2 mo | Primary outcome results: IIEF-5, mean (sd): IG1 vs. CG1: Baseline: 10 (1.3) vs. 10 (1.4) Post-tx: 15 (1.4) vs. 11 (1.5) IG2 vs. CG2: Baseline: 15 (1.6) vs. 15 (1.2) Post-tx: 17.5 (2) vs. 16 (1) Serum total T (nmol/L) level, IG+CG, baseline vs. post tx, mean (sd): 7.3 (1.4) vs. 11 (1.3) Other outcomes assessed: PADAM score mean (sd): baseline 28.4 (2) vs. post tx 22.4 (1.3); serum FSH, LH, PRL levels Withdrawals/drop-outs/loss to f/u: None WDAE: None TAE, n: 3, headache (sildenafil 100 mg) SAE: None Ascertainment of outcomes assessed: partial androgen deficiency in aging men (PADAM) rating score and IIEF-5 questionnaires
Wang (2000) ^244^ Funding source: Unimed Pharnaceuticals Inc Grant from NIH GrantM0-00543 | N screened = NR N randomized = 227 (16 centres) IG1, n = 73 IG2, n = 78 IG3, n = 76 CG, n = NA ITT analysis used for primary outcome: Inclusion: men with morning T ≤ 10.4 nmol/L (300 ng/dL); clinically healthy, if on lipid lowering agents or tranquilizers: dose stabilized for at least 3 mo prior to screening. Exclusion: hx of chronic medical illness or alcohol and drug use; presence of a generalized skin dx, hx of skin irritability with T patches; Ideal body weight < 80% or > 140 % | Age, mean: 58 y Race (%): NR Co-morbidities: NR Previous ED treatment: NR BMI, mean: all pts 30 kg/m^2^ Smoking status: NR Body weight, mean range: 95–99 kg Other: Testosterone (nmol/L) all pts: 10.4–34.7; Mean (sd): 234 (57) vs. 232 (62) vs. 239 (69) vs. 229 (80) ng/dL Sexual function (likert scale), mean (sd) Baseline: 2 (1) vs. 3 (1) vs. 2 (1) vs. 2 (1) | Concomitant medications: NR Duration of ED: NR Underlying disease: primary 6%, or secondary hypogonadal 94% (58–71% due to aging 19–32% due to normogonadotrophic) Psychogenic ED: NR Physiologic ED: all 100% Mixed ED: NR | IG1/ IG2: Testosterone transdermal gel IG3: Testosterone patch IG1: Dose: 50 mg/d (↑ to75 mg/d at 90 d in n=20 with T <10.4nmol/l at 60) Duration: 180 d Frequency: daily Compliance: 93% IG2: Dose: 100 mg/d (↓ to 75 mg/d at 90 d if T >34.7 nmol/l at 60 d) Duration: as IG Frequency: daily Compliance: 96% IG3: Dose: 2 patch, 5 mg/d Duration: 180 d Frequency: daily Compliance: 65% (1^st^ 90 d); 74% (2^nd^ 90 d) Run In period: 7 d Wash out period: NR F/u duration: 180 d (f/u at 0 and every 30 d) | Primary outcome results: Self assessment: Satisfaction of erection: ▴ from baseline in both grps, p=0.0001 % of full erection: ▴ from baseline in both grps, p=0.0001 (slightly better in 100 mg/d T gel) Other outcomes assessed: sexual function (desire, enjoyment, motivation, performance) and mood; lean mass, muscle strength, ▾ fat mass all improved with T gel and T patch with less skin irritation using T gel Withdrawals/drop-outs/loss to f/u, n (%): 17 (22.4) vs. 8 (5.3) WDAE, n (%): 17 (22.4) vs. 8 (5.3) TAE, n (%): skin irritation 5.5% with T gel, vs. 66% in T patch; other PSA elevation; depression memory loss, high blood pressure, Hct and Hgb rise (in T patch); gynecomastia; transient abnormal laboratory tests, headache, asthma, hypertension, dizziness anxiety and nervousness SAE, n (%): 0 Ascertainment of outcomes assessed: pts questionnaire, laboratory and clinical examination
Yassin (2006) ^245^ Funding source: NR | N screened = N randomized = 69 (open label randomized) IG1, n = 35 IG2, n = 34 ITT analysis used for primary outcome: NR Inclusion: hypogonadal (serum T 3.4 ngml^-1^ or less) age 34–78 y, with at least 6 mo hx of ED of any severity; hx of no response to 6–8 attempts with 20 mg tadalafil (poor EF score, persistent dissatisfaction) Exclusion: clinically sign disease known to contradict with T or tadalafil; severe DM, IPSS > 18; prostatitis, hyperprolactinaemia (>20 ngml^-1^); CV attacks in last 6 mo | Age, mean (sd): 58.3 (9.7) vs. 59.9 (9.1) y Race: NR Co-morbidities, n (%): DM type I 2 (5.9) vs.0; DM type II 6 (17.6) vs. 5 (14.3); hypertension 11 (32.4) vs. 13 (37.1); dyslipidaemia 7 (20.6) vs. 6 (17.1); BPH/LUTS 16 (47.1) vs. 11 (31.4) Previous ED treatment: all ptshad tadalafil monotherapy Smoking status: 13 (38.2) vs. 15 (42.9) Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): hypogonadalism Psychogenic ED, n (%): 0 Physiologic ED, n (%): 100% Mixed ED, n (%): 0 Other: ED severity, n (%): midland moderate 23 (67.7) vs. 26 (74.3); severe 12 (35.3) vs. 8 (22.9) Mean IPSS: 15 (both grps) | IG: sildenafil + T gel (Testogel®) CG: T gel alone IG1: Dose: 20 m sildenafil + 5 g containing 50 mg T Duration: 10 wks Frequency: sildenafil twice/wk; T gel NR Compliance: 100% IG2: Dose: 5 g containing 5 mg T Duration: 10 wks Frequency: NR Compliance: Run In period: 4 wks T gel tx Wash out period: 2 wks (post tadalafil Monotherapy) F/u duration: 10 wks Other: IG CG were assigned to add tadalafil to T tx at the end of 10 wk trial | Primary outcome results: Mean (sd), IG1 vs. IG2 IIEF-EF domain: Baseline 11.3 (3.0) vs. 11.3 (2.8) 10 wks: 18.3 (0.2) vs. 18.2 (0.4) (% improved in IIEF-EF with T-gel monotherapy in IG1 wk 4 = 43% vs. IG2 at wk 10 65%) IIEF-OF: Baseline 5.4 (2.6) 10 wks: 7.1 (1.4) vs. 7.1 (0.3) IIEF SD: Baseline 6.1 (2.8) 10 wks: 8.7 (0.8) vs. 7.8 (0.9) IIEF-IS: Baseline 8.9 (1.6) 10 wks: 13.1 (1.4) vs. 12.8 (1.2) IIEF-OS: Baseline 5.0 (1.5) 10 wks 8.2 (0.4) vs. 8.6 (0.3) Other outcomes assessed: partner satisfaction Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE: 0 TAE: 0 SAE: 0 Ascertainment of outcomes assessed: Serum hormone analysis; IIEF; pts and partner questionnaire on efficacy of erectile quality/rigidity

List of abbreviations: %=percent, ▴=increased, ▾=decreased, AE=adverse event, SAE=serious adverse event, BMI=body mass index, CC=controlled clinical trials, CG=comparator/control group, ctrls=controls, DM=diabetes mellitus, E_1_ IC=intracavernosal injection, ECG=electrocardiograms, ED=erectile dysfunction, EDV=end-diastolic velocity, f/u=follow-up, FMD=flow mediated dilation, GAQ=global assessment question, GEQ=global efficacy question, grp=group/s, HbA1C=haemoglobin, hr=hour(s), hx=history, IG=intervention group, IIEF= international index of erectile function (EF=erectile function, OF=orgasmic function, OS=overall satisfaction, SD=sexual desire), ITT=intent-to-treat (Y = yes, N = no, NR = not reported), IU=intraurethral, kg=kilograms, lbs=pounds, LUTS=lower urinary tract symptoms, M=male, max=maximum, mo=month(s), NA=not applicable, PADAM=partial androgen deficiency of the aging male, PgE_1_=Prostagladin, PRL=prolactin, PSA=prostate-specific antigen, RAU=rigidity activity unit, RCT=randomized control trial, SBP=systolic blood pressure, sign.=significant; TAE=total adverse events, TAU=tumescence activity unit, vs.=versus, WDAE=withdrawals resulting from adverse events, wk=week(s), yr=year(s).

Evidence Table C10. Off Label Treatments

Author Funding | N; study design; eligibility | Participants characteristics | Diagnosis details | Intervention | Outcomes
Aydin (1996) ^246^ Funding source: NR | N screened = NR N randomized = 79 IG1, n = 20 IG2, n = 21 IG3, n = 20 CG, n = Placebo ITT analysis used for primary outcome: Inclusion: men of various ages with hx of ED confirmed with clinical examination Exclusion: NR | Age, mean (sd): 38 (11.3) y Race: NR Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): NR Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG1: Testosterone IG2: Tradazone IG3: Hypnosis CG: Placebo IG1: Dose: 120 mg/d Duration: 16 wks Frequency: daily Compliance: NR IG2: Dose: 100–150 mg/d Duration: as IG1 Frequency: as IG1 Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: NR Wash out period: NR F/u duration: 16 wks | Primary outcome results: Improved in sexual function (full erection or ability to have intercourse with occasional failure), n (%): IG1: 12 (60) IG2: 14 (66.7) IG3: 16 (80) CG: 7 (38.9) Overall improvement achieved by 60, 67, and 80% of IG1, IG2, and IG3 respectively Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): NR TAE, n (%): 0 vs. 5 (23.8) vs. 0 vs. 0; pts in trazadone grp experienced sedation SAE, n (%): NR Ascertainment of outcomes assessed: pts diary
Becker (1998) ^247^ Funding source: Zonagen USA | N screened = 40 N randomized = 40 IG1, n = 10 IG2, n = 10 IG3, n = 10 CG, n = 10 ITT analysis used for primary outcome: NR Inclusion: hx of ED for less than3 y; ED likely to be organic who not responded positively to placebo test Exclusion: CVA; DM, neurological disease, tolerance to the study medication | Age, mean (range): 48 (26–70) y Race: NR Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: NR | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): NR Psychogenic ED, n (%): NR Physiologic ED, n (%): likely 100% Mixed ED, n (%): NR | IG: Phentolamine CG: Placebo IG1-3: Dose: 20 mg (IG1), 40 mg (IG2), 60 mg (IG3) Duration: NR Frequency: NR Compliance: NR CG: Dose: NA Duration: as IG Frequency: NR Compliance: NR Run In period: NR Wash out period: NA F/u duration: NR | Primary outcome results: Full erection (sufficient for vaginal penetration), n (%): IG1: 3 (30) IG2: 5 (50) IG3: 4 (40) CG: 2 (20) Other outcomes assessed: NA Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): 0 TAE, n (%): 1 events (stuffy nose) only with 60 mg SAE, n (%): 0 Ascertainment of outcomes assessed: pts diary
Costabile, R. (1999) ^248^ Funding source: NR | N screened = NR N randomized = 51 cross over IG screened = NR IG randomized = 51 cross over CG screened = NR CG randomized = 51 cross over Inclusion: At least 3 mos. of ED Exclusion: Pts with sign. cardiac disease | Age, mean (range): 65 yrs (range 31–80) Race (%): NR Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C)(%): NR Previous ED treatment: NR BMI (kg/m^2^): NR Smoking status: NR Initial body weight: NR Other: NA | Concomitant medications: NR Duration of ED (mos./ yr)(mean [range]): 36 mos. (range 4 mos.- 30 yrs) Underlying disease (diagnosis) (N or % of diseased/grp): NR Psychogenic ED (N [%]: psychogenic 4(2) Physiologic ED (N [%]: arterial insufficiency 39(20), hypertension 18(9), diabetes 12(6), veno-occlusive dysfunction 10(5), surgical 6(3), neurogenic 4(2) Unknown ED (N [%]: unknown 7(4) Other: NA | IG: trazodone, oral CG: placebo, oral IG: Dose: 50 mg Duration: 3 mos. Frequency: 1/d, bedtime Compliance: 94% 1 CG: Dose: 50 mg Duration: 3 mos. Frequency: 1/d, bedtime Compliance: 94% 1 Run In period: 3 nights Wash out period: 3 wks F/u duration (both on and off treatment): NA Other: NA | Primary outcome results: Index of sexual satisfaction (mean): IG 27.5, CG 30.8 = no sign. difference Patient diary evaluations (%): first treatment interval, erection improvement IG 19, CG 24; sex drive improvement IG 35, CG 40 = no sign. difference when both treatment intervals combined List (narrative) other outcomes assessed: physical examination, laboratory evaluations, pre screening penile Doppler ultrasound ITT analysis used for primary outcome? N Withdrawals/drop-outs/loss to f/u [N and/or %]: N=3 WDAE (N and/or %): NR TAE (N [%]): dry mouth IG 12(25), CG 8(16.7); drowsiness IG 9(18.8), CG 6(12.5); fatigue IG 7(14.6), CG 4(8.3) SAE: NR Ascertainment of outcomes assessed: Index of sexual satisfaction: details not provided. Patient diary evaluations: self reported, administered monthly, documented sexual activity, libido and AE, extracted 2 questions-did this medicine improve your erection? did you notice a change in your sex drive while taking this medicine?
Enzlin, P (2000) ^249^ Funding source: Searle Continental Pharma Inc. | N screened = 39 N randomized = 34 IG1 randomized = 16 IG2 randomized = NA CG randomized = 17 Inclusion: age 18–65; in stable heterosexual relationship for ≥6 mo; ED ≥4 mo Exclusion: ED caused by sickle cell anemia and trait, thyroid or endocrine disorders (except diabetes), spinal cord lesion, or pelvic surgery or trauma; hx of myocardial infarction, coronary angioplasty or coronary bypass graft surgery in past 3 mo (except antihypertensive drugs since 2 mo before onset of ED); ejaculation disorder; medication known to possibly cause ED | Age, mean (sd): IG1 49 (11) CG 46 (8) Race (%): NR Co-morbidities (unrelated to disease): Diabetes 1 Blood glucose (or HbA1C)(%): NR Previous ED treatment: NR BMI (kg/m^2^): NR Smoking status: NR Initial body weight: NR | Concomitant medications: Antihypertensives 1 Duration of ED (yr): NR Underlying disease (diagnosis) (N or % of diseased/ grp): NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: trazodone orally IG2: NA CG: placebo orally IG1: Dose: 200 mg Duration: 4 wk Frequency: 1 dose/day Compliance (%): 1 wk: 71.4% good 4 wk: 57.1% good IG2: NA Dose: Duration: Frequency: Compliance (%): CG: Dose: placebo Duration: 4 wk Frequency: 1 dose/day Compliance (%): NR Run In period: 2 wk, including 2 or 3 nights of adaptation with RigiScan Plus® Wash out period: NA F/u duration (both on and off treatment): 4 wk and 2 or 3 days | Primary outcome results: Mean difference in total duration of nocturnal erection, minutes Base IG1 ▴ 8, CG ▴ 3 Tip IG1 ▴ 7, CG ▾ 4 List (narrative) other outcomes assessed: Rigidity and tumescence; SD (Derogatis Sexual Functioning Inventory); quality of partner relationship (Dyadic Adjustment scale); depressive symptoms (Hamilton Depression Rating scale) ITT analysis used for primary outcome? N Withdrawals/drop-outs/loss to f/u [N and/or %]: 1 (CG) WDAE (N and/or %): NR TAE: NR SAE: NR Ascertainment of outcomes assessed: RigiScan Plus® Rigidity Assessment System Other: Not a very well reported study
Georgitis, W. (1995) ^250^ Funding source: U.S. Army Health Services Command | N screened = NR N randomized = NR IG1, n = 34 CG, n = 26 ITT analysis used for primary outcome: NR Inclusion: Non insulin-dependent DM men Patients with fasting serum glucose > 200mg/dl or HbA_1c_>10% included only if impotence persisted after improved glycemic control Exclusion: Patients receiving anticoagulants, with past Hx of peptic ulcer disease or whose impotence was not cause by diabetes. Patients on beta-blockers, aldomet or clonidine excluded | Age: Mean IG1: 59.1 ± 6.4 Mean CG: 64.6 ± 7.6 Race: (n) Black: 20; Hispanic: 5; White: 35 Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C): Initial: IG1 vs. CG: 8.1 ± 1.8 vs. 7.4± 1.5. End: 8.0 ± 1.7 vs. 7.2 ± 1.3 Previous ED treatment: NR BMI (kg/m^2^): Mean IG1 vs. CG: 28.0 ± 4.2 vs. 28.5 ± 3.0 Smoking status: IG1 vs. C: Active 3 vs. 8; Quit: 15 vs. 19; Nonsmokers: 8 vs. 7 Pack yrs: 39 ± 5 vs. 37 ±9 Body weight: NR | Concomitant medications: NR Duration of ED: IG1 vs CG: 5.2 ± 3.8 vs 6.0 ± 5.0 Underlying disease (diagnosis): Diabetes Duration (yrs): IG1:13.6 ± 8.7 CG: 14.2 ± 10.9 Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: Treatment for diabetes, IG1 vs CG: Diet:3 vs 0. Oral:18 vs 12. Insulin:13 vs 9. Combination: 0 vs 2 Onset of ED, gradual/abrupt IG1 vs CG: 31/3 vs 24/2 Duration of hypertension, IG1 vs CG:16.6 ± 12.6 vs 10.9 ± 8.6 yrs Ankle brachial SBP ratios abnormal in 6% of IG1 vs 0% CG Penile brachial blood pressure rations abnormal in 38& of IG1 vs 27% CG Autonomic dysfunction in IG1 vs CG: 82% vs 100%. | IG1: Oral Pentoxifylline (Trental™) CG: Placebo IG1: Pentoxifylline Dose: 400 mg Duration: 3 mo Frequency: 3/day Compliance (%): NR CG: Placebo Dose: N/A Duration: 3 mo Frequency: 3/day Compliance (%): NR Run In period: NR Wash out period: NR F/u duration (on and off treatment): 3 mo Other: NR | Primary outcome results: Self reported EF: IG1 vs CG: No difference Frequency of nocturnal penile tumescence IG1 vs CG: No difference Frequency of attempted intercourse or desired intercourse IG1 vs CG: No difference Other outcomes assessed: Rigidity, change in tumescence, erectile events /night, all abnormal in both IG1 and CG at baseline: No improvement observed in both IG1 and CG after 3 mo Withdrawals/drop-outs/loss to f/u: NR WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: Self assessed EF using questionnaire and Likert scale at 3 time points Nocturnal penile tumescence: Monitored at 3 time points before and after intervention using RigiScan™ monitor. Peripheral vascular measurements done by Doppler ultrasound using Model 1059 Mini-lab III and a PVR IV Pulse Volume recorder
Hatzichristou (2001) ^251^ Funding source: Schering-Plough Corporation | N screened = NR N randomized = NR IG1 randomized = 5 CG randomized = 5 Inclusion: hx of ED ≥ 3mons, mild to moderate ED defined from IIEF Exclusion: impotence caused by untreated endocrine disease, penile curvature, clinical hx of sign. liver or renal disease, symptomatic uncontrolled heart disease, concomitant nitrate therapy for underlying condition; sitting or supine SBP > 160 mmHg or diastolic > 95mmHg, symptomatic postural hypotension < 6 mons, psychoses, uncontrolled bipolar disorder or depression, prior or current use of therapy for ED | Age, mean (SE): 34.8 (8.13) Race (%): NR Co-morbidities (unrelated to disease): 1 person had pulmonary disease, 1 had prostatitis-like syndrome Blood glucose (or HbA1C)(%): NR Previous ED treatment: None BMI (kg/m^2^): NR Smoking status: NR Initial body weight: NR | Concomitant medications: NR Duration of ED (mons) mean (SE): 31.8 (23.56) Underlying disease (diagnosis) (N or % of diseased/ grp): Mild arteriogenic ED: n = 1 Mild veno-occlusive dysfunction: n= 2 Psychogenic ED: 0 Physiologic ED: 5 Mixed ED: 0 | IG1: oral phentolamine (Vasomax) tablets CG: oral placebo tablets IG1: Dose: 40 milligrams Duration: 3 nights Frequency: 1×/ night Compliance (%): 100% CG: Dose: NA Duration: 3 nights Frequency: 1×/night Compliance (%): 100% Run In period: NR Wash out period: ≥ 6 days, ≤ 30 days F/u duration (both on and off treatment): NR | Primary outcome results: Penile tumescence (non sig.) Penile rigidity at tip: IG1: 5.24 ± 1.6, at base, 5.77 ± 1.62 IG1: ▴mean erectile events/sleep hr: 0.24 ± .08 CG: 0.13 ± .05 IG1: ▴mean duration of events: 5.53 ± 2.57 CG: 2.6 ± 1.04 List (narrative) other outcomes assessed: None ITT analysis used for primary outcome? No Withdrawals/drop-outs/loss to f/u [N and or %]: 0 WDAE (N and/or %): 0 TAE: 0 SAE: 0 Ascertainment of outcomes assessed: RigiScan device, medical an sexual hx, IIEF score
Korenman (1993) ^252^ Funding source: | N screened = 24 N randomized = 18 IG1, n = 8 CG, n = 10 ITT analysis used for primary outcome: NR Inclusion: Borderline to definite penile arterial insufficiency as determined by PBPI, interest to re-establish EF by both partners and willingness to participate. Exclusion: Actively progressive illness, severe physical disability, major mental or emotional disease, hepatic or renal insufficient, hx of major cardiac arrhythmia, abuse of alcohol and other substances, and those lacking sexual partner. Other: Open label study was done after initial 12 wks finished. All 18 pts went on drug. | Age, mean (range): 65 ± 1.4 (54–76) Race: NR Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C): NR Previous ED treatment: NR BMI (kg/m^2^): NR Smoking status: NR Body weight: NR | Concomitant medications: NR Duration of ED: 6.2 ± 1.1 y Underlying disease (diagnosis): n(%) Hypertension 13 (72.2); Diabetes 6 (33.3); ASCVD 10 (55.6); Hypogonadism 4 (22.2); Compensated hypergonadotropic hypogonadism 1 (5.6) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: Pentoxifylline CG: Placebo IG1: Dose: 400mg Duration: 12 wks Frequency: NR Compliance (%): 100% CG: Dose: NR Duration: 12 wks Frequency: NR Compliance (%) 100%: Run In period: NR Wash out period: NR F/u duration (on and off treatment): NR | Primary outcome results: IG1 vs. CG n/N (%) No improvement (one episode of coitus) 4/8 (50) vs. 10/10 (100) Pentoxifylline improved the PBPI in 18 males (0.76 ± 0.01, p = <0.0001) Other outcomes assessed: Patients initially receiving placebo placed on pentoxifylline: 5/10 (50) experienced successful intercourse. Pentoxifylline improved the PBPI in 18 males 0.76 (0.01), mean (sd) 9 (50) improved into normal range Withdrawals/drop-outs/loss to f/u: None WDAE: None TAE: None SAE: None Ascertainment of outcomes assessed: Report of patient verified by partner; penile-brachial pressure index determination (PBPI), daily log of improvement in EF.
Kurt, U. (1994) ^253^ Funding source: NR | N screened = N randomized = 100 IG1, n = 25 IG2, n = 25 IG3, n = 25 CG, n = 25 ITT analysis used for primary outcome: NR Inclusion: ED ≥ 6 mo. < I coitus within several 30 day periods. Absence of normal sexual performance periods in last 6 mo. Sufficient libido, no ejaculation problems. Absence of specific diseases: Eg. DM, neurological disorders, atherosclerotic vascular disease. No Hx of chronic or recent psychological problem. No Hx of recent trauma interfering with neurorvascular structures related to erections. Positive papaverine test (30–60 mg IC) producing a rigid > 30 min erection. Exclusion: NR | Age: Mean 47.0 (range 23–68) yrs Race: NR Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C): NR Previous ED treatment: NR BMI (kg/m^2^): NR Smoking status: NR Body weight: NR Other: NR | Concomitant medications: NR Duration of ED: NR Underlying disease (diagnosis): NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other NR | IG1: Oral Trazodone IG2: Oral Ketanserin IG3: Oral Mianserin CG: Placebo IG1: Trazodone Dose: 50 mg Duration: 30 days Frequency: 3/day Compliance (%): NR IG2: Ketanserin Dose: 20 mg Duration: 30 days Frequency: 2/ day Compliance (%): NR IG3: Mianserin Dose: 10 mg Duration: 30 days Frequency: 3/ day Compliance (%): NR CG: Dose: placebo Duration: 30 days Frequency: NR Compliance (%): NR Run In period: Wash out period: NR F/u duration (on and off treatment): 30 days Other: NR | Primary outcome results: Positive response rate: IG1> IG3> IG2> CG (p=0.0004 in IG1 vs. CG) (p= 0.002 in IG1 vs. IG2) (p= 0.03 in IG1 vs. IG3) IG2 and IG3 Not sign. vs. CG Other outcomes assessed: NR Withdrawals/drop-outs/loss to f/u: Total N = 15 5 = loss to f/u 3= preferred IC treatment 2= preferred vacuum device 2= Hx concomitant drug use 2= social reasons 1= penile implant inserted Final analysis value: IG1: 23, IG2: 21, IG3: 19, CG: 22 WDAE: TAE: IG1: N=5: Sedation (n=2), Xerostomia (n=2), blurred vision (n=1) IG2: N=2: Vertigo (n=1), Fatigue (n=1) IG3: N=2: Severe sedation (n=2) CG: N= 2: Nausea (n=2) SAE: IG1: priapism in 1 patient 7 days after onset of intervention. IG1: severe sedation in 1 patient requiring cessation Ascertainment of outcomes assessed: Positive response= 3+ successful intercourse events without manipulation (in patient with previously inadequate rigidity without manipulation)
Mann, K (2001) ^254^ Funding source: Hoffmann-La Roche, Grenzach-Wyhlen | N screened = NR N randomized = 13 IG1 screened = NR IG1 randomized = 6 IG2 screened = NA IG2 randomized = CG screened = NR CG randomized = 7 Inclusion: ED Exclusion: lifetime diagnosis of any psychiatric disorder except for sexual dysfunction; hx of alcohol or other substance abuse; current or recent evidence of sign. medical disorder; sleep disturbances; taking any drugs | Age, mean (sd): IG1 49.3 (SD 8.9) CG 37.8 (SD 8.2) Race (%): NR Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C)(%): NR Previous ED treatment: NR BMI (kg/m^2^): NR Smoking status: NR Initial body weight: NR Other: Degree of severity of ED (Clinical Global Impression scale, mean [and standard error]) IG1 5.17 (0.31) CG 5.00 (0.37) | Concomitant medications: NR Duration of ED (yr): IG1 3.8, CG 2.8 Underlying disease (diagnosis) (N or % of diseased/grp): NR Psychogenic ED: 13 Physiologic ED: 0 Mixed ED: 0 | IG1: moclobemide orally orally IG2: NA CG: placebo orally IG1: Dose: 450 mg during wk 1, 600 mg during wk 2–8 Duration: 8 wk Frequency: 1 dose/day Compliance (%): NR IG2: NA Dose: Duration: Frequency: Compliance (%): CG: Dose: placebo Duration: 8 wk Frequency: 1 dose/day Compliance (%): NR Run In period: NR Wash out period: NA F/u duration (both on and off treatment): 8 wk | Primary outcome results: Clinical Global Impression severity subscale at 8 wk (1=normal, 2=borderline ill, 3=mildly ill, 4=moderately ill, 5=markedly ill, 6=severely ill, 7=among most extremely ill) IG1 3.50, CG 4.50 Clinical Global Impression improvement subscale at 8 wk (-3=very much worse, -2=much worse, -1=minimally worse, 0=no change, 1=minimally improved, 2=much improved, 3=very much improved) IG1 1.50, CG 0.50 Change in mean nocturnal tumescence and rigidity of penis base and tip (averaged of the two) at 8 wk Tumescence, cm: IG1 -0.24, CG -0.13 Rigidity, %: IG1 2.58, CG 2.67 List (narrative) other outcomes assessed: NA ITT analysis used for primary outcome? Y N/NR N Withdrawals/drop-outs/loss to f/u [N and/or %]: 1 (CG) WDAE (N and/or %): 1 (CG) TAE: IG1: 4 events in 3 patients CG: 7 events in 3 patients SAE: 0 Ascertainment of outcomes assessed: RigiScan™ Rigidity Assessment System
Meinhardt, W. (1997) ^255^ Funding source: NR | N screened = NR N randomized = 69 IG screened = NR IG randomized = 32 CG screened = NR CG randomized = 37 Inclusion: ED Exclusion: severe kidney or liver disorders, pts using anti-hypertensives or other drugs (especially alpha or beta blocking agents) | Age, mean (range): IG 54(26–80), CG 55(39–81) Race (%): Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C)(%): NR Previous ED treatment (N): self-injections IG 5, CG 16; psychotherapy IG 1, CG 0; vacuum device IG 1, CG 1 BMI (kg/m^2^): NR Smoking status: NR Initial body weight: NR Other: NA | Concomitant medications: NR Duration of ED (yr): NR Underlying disease (diagnosis) (N or % of diseased/grp): ED 69(100) Psychogenic ED (N): IG 16, CG 20 Physiologic ED (N): vascular IG 5, CG 5; diabetes IG 5, CG 7; neurogenic IG 1, CG 0; peyronie's disease IG 1, CG 1; Mixed/unknown ED: IG 4, CG 4 Other: NA | IG: trazodone, oral CG: placebo, oral IG: Dose: 50 mg Duration: 4 or 6 wks Frequency: X3/d = 150 mg Compliance (%): NR CG: Dose: 50 mg Duration: 4 or 6 wks Frequency: X3/d = 150 mg Compliance (%): NR Run In period: 2 wks Wash out period: NA F/u duration (both on and off treatment): NA Other: NA | Primary outcome results: Patients diary: NR in results Questionnaire (N [%]): medication did not work IG 15(58), CG 20(62); it works, but insufficiently IG 6(23), CG 6(19); it works, but too many side-effects IG 1(4), CG 1(3); medication works well IG 4(15), CG 5(16) = [p> 0.05] for all List (narrative) other outcomes assessed: RigiScan ITT analysis used for primary outcome? N Withdrawals/drop-outs/loss to f/u [N and or %]: N=2 lost to f/u WDAE (N and/or %): N= 6,7 or 9 side effects TAE: dizziness IG 5, CG 0; sleepiness IG5, CG 2; headache IG 3, CG 1; nausea IG 3, CG 0; rash IG 0, CG 1; conjunctivitis IG 0, CG 1 SAE: NR Ascertainment of outcomes assessed: Patients diary: details on sexual function and complaints Questionnaire: opinion of treatment Other: NA
Nickle (2007) ^256^ Funding source: NR | N screened = N randomized = 50 IG, n = 25 CG, n = 25 ITT analysis used for primary outcome: NR Inclusion: men > 18 y, suffering from chronic stress and anxious or depressive mood with ED Exclusion: psychotic disorders, organic ED, current use of cabergoline, other dopamine agonists, any kind of current anti-ED, use of antidepressants, antianxiety drugs or psychotherapy | Age, mean (sd): 39.3 (15.3) vs. 38.8 (12.9) y Race: NR Co-morbidities, n (%): NR Previous ED treatment: Smoking status: Body weight: NR Other: BMI: 26.1 (5.9) vs. 26.9 (5.4) | Concomitant medications, n (%): NR Duration of ED: > 6 mo Underlying disease, n (%): as in inclusion Psychogenic ED, n (%): 100% Physiologic ED, n (%): 0 Mixed ED, n (%): NR Other: moderate baseline hyperprolactinemia in 38 (18 vs. 20) | IG: Cabergoline CG: Placebo IG: Dose: 0.5 mg Duration: 4 mo Frequency: once/d Compliance: NR CG: Dose: NA Duration: 4 mo Frequency: as IG Compliance: NR Run In period: NR Wash out period: NR F/u duration: 4 mo | Primary outcome (EF): Improvement from baseline (in mean): IIEF-EF: 11.7 vs. 6.9 IIEF-OF: 3.6 vs. 1.8 IIEF-IS: 5.7 vs. 2.6 IIEF-OS: 3.6 vs. 0.9 IIEF-SD: 3.5 vs. 2.0 ED-QoL change from baseline score: -16.9 vs. -9.6 Other outcomes assessed: SFQ partner questionnaire Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): NR TAE, n (%): 10 (40) vs. 9 (36) SAE, n (%): NR Ascertainment of outcomes assessed: IIEF domains; ED quality of life questionnaire
Peskircioglu (1996) ^257^ Funding source: NR | N screened = NR N randomized = 36 IG1 randomized =20 CG randomized = 16 Inclusion: patients with borderline arterial insufficiency Exclusion: patients with correctable secondary causes (endocrine, metabolic, pharmacological & Peyronie's disease) | Age, mean (sd): 54 (± 7) Race (%): NR Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C)(%): NR Previous ED treatment: NR BMI (kg/m^2^): NR Smoking status: NR Initial body weight: NR | Concomitant medications: NR Duration of ED (yr): NR Underlying disease (diagnosis) (N or % of diseased/ grp): NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: oral pentoxifylline CG: placebo (vitamin B complex) IG1: Dose: 1.2 grams in 3 doses Duration: 2 mons Frequency: 3 doses/day Compliance (%): 100 CG: Dose: NA Duration: 2 mons Frequency: 3 doses/day Compliance (%): 100 Run In period: NR Wash out period: NR F/u duration (both on and off treatment): NR | Primary outcome results: Penile blood flow IG1: 12/20 ▴ (mean change = 6.25 cm) CG: 4/20 ▴ (mean change = 0.38 cm) List (narrative) other outcomes assessed: Potency ITT analysis used for primary outcome? Withdrawals/drop-outs/loss to f/u [N and or %]: 0 WDAE (N and/or %): 0 TAE: IG1: n =2 (nausea), n = 2 (headache) SAE: 0 Ascertainment of outcomes assessed: Penile duplex ultrasonography
Piha J. (2003) ^258^ Funding source: Finnish Hypertension Society and Slovay Pharma/ Algol. | N screened = NR N randomized = 12 Crossover design IG1, n = 11 IG1 crossover, n = 11 ITT analysis used for primary outcome: Inclusion: Hypertensive Exclusion: NR | Age: Mean 50.5 (range 41–58) Race: NR Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C): NR Previous ED treatment: NR BMI (kg/m^2^): NR Smoking status: NR Body weight: NR Other: Mean IIEF-5 score: 15.8± 8.5 4= score ≥ 21 7= score <21 Mean serum T 13.1 ± 3.3 nmol/L Weekly resting Blood Pressure | Concomitant medications: For Hypertension (n): 2 on ACE inhibitor 5 on ACE inhibitor + beta-blocker + thiazide diuretic 1 on beta-blocker 2 on calcium cannel Duration of ED: NR Underlying disease (diagnosis): Hypertension Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR Other: NR | IG1: Moxonidine IG1 crossover: Metoprolol IG1: Moxonidine Dose: 0.4 mg ▴ 0.6mg if BP >160/100 mmHg Duration: 8 wks Frequency: daily Compliance (%): NR IG1 crossover: Metoprolo Dose: 100 mg ▴200 mg if needed Duration: 8wks Frequency: daily Compliance (%): NR Run In period: Wash out period: 1–3 days F/u duration (on and off treatment): 16 wks Other: NR | Primary outcome results: Resting vs. stimulated penile Peak artery velocity for IG1: Mean peak velocity ▴: 19.8 ± 5.8 vs. 64.0 ± 32.4 cm/sec (p=0.008) Resting vs. stimulated penile Peak artery velocity for IG1 crossover Mean peak velocity ▴: 15.6 ± 55.2 vs. 53.9 ± 26.4 cm/sec (p=0.038) Resting vs. stimulated penile diameter for IG1: ▴ diameter: 0.54 ± 0.13 vs. 0.89 ± 0.14 mm (p=0.004) Resting vs. stimulated penile diameter for IG1crossover: ▴ diameter: 0.43 ± 0.16 vs. 0.66 ± 0.14 mm (p= 0.0001) Other outcomes assessed: Patient reported Subjective Erectile capacity [underlined: improved:] IG1 vs. baseline: 9/11 (p<0.001). IG1 crossover vs. baseline: 9/11 reported [underlined: impaired] EF (p<0.0002) Withdrawals/drop-outs/loss to f/u: 1withdrawal due to not hypertensive (BP below 170/110 mmHg) WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: Stimulated erection induced by Alprostadil 10 microgram + phentolamine 0.1 mg IC. Peak systolic velocity measured via Doppler at 2 sites, mean of 4 measurements after 10–15 min Other: Mean Blood pressure with IG1 vs. IG1 crossover: 163.8 (± 16.0) / 96.2 (± 6.3) mmHg vs. 157.8 (± 19.2) / 93.6 (± 11.1) mmHg. P= not sign.
Reiter, WJ (1998) ^259^ Funding source: NR | N screened = NR N randomized = 40 IG1, n = 20 CG, n = 20 ITT analysis used for primary outcome: N Inclusion: hx of ED > 6 mos., serum levels of testosterone, PRL, and PSA within normal range, and serum DHEAS level < 1.5 μmol/L, International Prostate Symptom Score < 7, full erection after intracavernosal administration of 10 μg PGE1 Exclusion: well known causes of ED (hypertension, DM, ischemic heart disease, hyperlipidemia, neurological disorders, veno-occlusive dysfunction, and hx of radical prostatectomy) | Age [mean yr (range)]: IG 56.6(43–68), CG 56.4(41–69) Race: NR Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C): NR Previous ED treatment: NR BMI (kg/m^2^): NR Smoking status [N (%)]: non-smokers 40(100) Body weight: NR | Concomitant medications: NR Duration of ED: NR Underlying disease (diagnosis)[N (%)]: ED 40(100) Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: oral dehydroepiandrosterone (DHEA) CG: oral placebo DHEA IG1: Dose: 50 μg Duration: 24 wks Frequency: 1X/d Compliance: NR CG: Dose: 50 μg Duration: 24 wks Frequency: 1X/d Compliance: NR Run In period: NA Wash out period: NA F/u duration (on and off treatment): 24 wks (0, 8, 16, and 24 wks) | Primary outcome results: IIEF (~mean score /30): EF IG scored higher ~29 vs. CG ~8; OF IG scored higher ~10 vs. CG ~2; SD IG scored higher ~8 vs. CG ~2; intercourse satisfaction IG scored higher ~14 vs. CG ~4; OS IG scored higher ~9 vs. CG ~4 (no indication of sign.)(data provided in Figure 2) Testosterone serum levels (~ mean ng/ml): IG ~4.6 vs. CG ~3.6 no sign. difference (p >0.05)(data provided in Figure 1) DHEA serum levels (~ mean μg/ml): IG levels ▴~2.4 vs. CG ~1.0 (no indication of sign.)(data provided in Figure 1) Other outcomes assessed: PRL and PSA serum levels Withdrawals/drop-outs/loss to f/u (N): insufficient response IG 0, CG 6; inadequate PSA IG 0, CG 1 WDAE: NR TAE: NR SAE: NR Ascertainment of outcomes assessed: IIEF: 15-item questionnaire, questions rated 0–5. Testosterone serum levels: via blood sample. DHEA serum levels: via blood sample.
Safarinejad (2001) ^260^ Funding source: NR | N screened = 44 N randomized = 44 IG1 screened = 44 IG1 randomized =44 CG screened: 44 CG randomized: 44 Inclusion: No organic diseases, laboratory findings were normal, peak flow values on Duplex ultrasonaography were > 30cm/s in both cavernous arteries, the end diastolic flow on duplex Doppler ultrasonography was < 2cm/s, intra cavernous injection test produced good rigidity, neurologic findings were normal. Exclusion: clinically obvious psychogenic impotence, verified or suspected malignancy, diabetes, neurological problems such as parkinsonism and paraplegia, impotence of clearly arterial or venous origin, genital anomoly or disease, cardiovascular disorders | Age, mean (range): 42 (28–55) y Race (%): NR Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C)(%): NR Previous ED treatment: NR BMI (kg/m^2^): NR Smoking status: NR Initial body weight: NR | Concomitant Medications (n/grp): NR Duration of ED (yr): NR Underlying disease (diagnosis) (N or % of diseased/grp): NR Physiologic ED: NR Psychogenic ED: NR Mixed ED: 44 | IG1: isoxsuprine hydrochloride, oral medication (pill form) CG: oral medication (pill form) IG1: Dose: 60 milligrams Duration: 30 days Frequency: 1×/day Compliance (%): NR CG: Dose: NA Duration:30 days Frequency: 1×/day Compliance (%): 82 Run In period: NR Wash out period: 2 wks F/u duration (both on and off treatment): NR | Primary outcome results: Erectile response for IG1: n (%) - Complete: 3 (8.3); Partial: 3 (8.3); None: 27 (75); Worse: 3 (8.3) Erectile response for CG: n (%) - Complete: 3 (8.3); Partial: 4 (11); None: 29 (80.5); Worse: 0 List (narrative) other outcomes assessed: Pulse rate, blood pressure, Libido, orgasm, duration of erection, rigidity of penis ITT analysis used for primary outcome? Y N/NR: No Withdrawals/drop-outs/loss to f/u [N and/or %]: 6 WDAE (N and/or %): 2 (IG1, hypotension) TAE: 47 IG1: n (%) - ▾ arterial pressure: 8 (22.2); Headache: 7 (19.4) Trembling: 3 (8.3); Nervousness: 4 (11.1); Gastrointestinal problems: 9 (25) Skin rash: 4 (11.1); Facial redness: 4 (11.1); Tachycardia: 2 (5.55) CG: n (%) - Headache: 2 (5.55); Skin rash: 2 (5.55); Tachychardia: 3 (8.3) SAE: 0 Ascertainment of outcomes assessed: Doppler ultrasonography, patient perception questionnaire, laboratory tests
Sommer (2006) ^261^ Funding source: NR (medication by LO.LI Pharma Co. Italy) | N screened = NR N randomized = 176 IG, n = NR CG, n = NR ITT analysis used for primary outcome: NR Inclusion: men with diagnosed DM type II and ED of longer than 6 mo who were in stable relationships Exclusion: current or recent ED treatment (including vacuum devices, IC or IU injections) | Age, range: 50–70 y Race: NR Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: BMI, mean (sem) 26.2 (3.5) vs. 27.4 (3.0) kg/m^2^ | Concomitant medications, n (%): NR Duration of ED: > 6 mo Underlying disease, n (%): NR Psychogenic ED, n (%): 0 Physiologic ED, n (%): 100% Mixed ED, n (%): NR | IG: Myoinositol/folic acid combination (oral) CG: Placebo IG: Dose: 4 g/400 μg Duration: 12 wks Frequency: once/d Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: 2 wks Wash out period: NA F/u duration: 90 d | Primary outcome results: IIEF-5 score, mean (sem): Baseline: 12 (5) vs. 14 (4) Post tx: 20 (3) vs. 13 (4) Sexual function, mean (sem) Baseline: 8 (3) vs. 9 (2) Post tx: 11 (1) vs. 9 (1) Sexual diary, mean (sem) Baseline: 1 (1) vs. 1 (1) Post tx: 6 (1) vs. 3 (1) Other outcomes assessed: PSV, EDV and RI (resistance index); results indicated sign. improvement in PSV and EDV after tx in IG only (p<0.05) Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): NR TAE, n (%): NR SAE, n (%): NR Ascertainment of outcomes assessed: IIEF-5, pts diary
Sommer (2006) ^262^ Funding source: NR | N screened = 237 N randomized = 68 (cross over design) IG/CG, n = 68 ITT analysis used for primary outcome: NR Inclusion: men 18 or older, with diagnosed depressive disorder and ED of longer than 6 mo who were in stable relationships Exclusion: other axis I psychiatric disorder (i.e. substance abuse or dependence), use of any antidepressant medication, abnormal serum hormone levels, hx of major organ disease or poorly controlled DM | Age, mean (sd): 36.1 (6.7) vs. 35 (8.3) Race: NR Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: NR Other: BMI, mean (sem) 26.2 (3.5) vs. 27.4 (3.0) kg/m^2^ | Concomitant medications, n (%): NR Duration of ED: 6.5 (1.4) VS. 7.2 (1.5) y Underlying disease, n (%): NR Psychogenic ED, n (%): 100% Physiologic ED, n (%): 0 Mixed ED, n (%): NR | IG: Tianeptine (oral) CG: Placebo IG: Dose: NR Duration: 8 wks Frequency: once/d Compliance: NR CG: Dose: NA Duration: as IG Frequency: as IG Compliance: NR Run In period: 4 wks Wash out period: NR F/u duration: 8 and 16 wks (end of each cross over tx phase) | Primary outcome results: Brief Sexual Inventory score for erection, mean (sd): Baseline: 5.4 (1.9) vs. 4.1 (2.3) Post tx: 8.5 (2.4) vs. 5.7 (1.1), p<0.05 GAQ, % yes (successful sexual intercourse): 89.4% vs. 50% Responders: 48 (72.2%) vs. 19 (27.9%) Other outcomes assessed: depressive scores (ED improvement highly correlated with changes in depressive symptoms) Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): NR TAE, n (%): 5 (3.4) vs. 1 (1.5) including headache, GI or CNS symptoms SAE, n (%): NR Ascertainment of outcomes assessed: Anxiety Depression Scale, Brief Sexual Inventory, and QoL and erection questionnaire; GAQ
Sommer (2006) ^263^ Funding source: NR | N screened = NR N randomized = 18 (likely parallel) IG1, n = NR IG2, n = NR CG, n = NR ITT analysis used for primary outcome: yes Inclusion: men 21–62 y; diagnosed with ED (by IIEF-EF) Exclusion: ED due to any neurological on endocrine causes, an anatomical deformity such as severe penile fibrosis, SCI or radical prostatectomy, DM, other relevant co morbidities, major psychiatric illness or concomitant tx | Age, mean (sd): 41.6 (11.9) y Race: 100% White Co-morbidities, n (%): NR Previous ED treatment: NR Smoking status: NR Body weight: 78.8 (7.9) kg Other: IIEF-EF baseline: range 14–19 | Concomitant medications, n (%): NR Duration of ED: NR Underlying disease, n (%): NR Psychogenic ED, n (%): NR Physiologic ED, n (%): NR Mixed ED, n (%): NR | IG1-2: Tetrahydobiopterine (BH_4_) + VSS CG: Placebo IG1/2: Dose: 200 mg or 500 mg Duration: NA Frequency: single dose Compliance: 100% CG: Dose: NA Duration: NA Frequency: as IG Compliance: 100% Run In period: NR Wash out period: NR F/u duration: NR | Primary outcome results: Time, base rigidity 60–100%, mean (sd): 71.6 (40.5) vs. 74.2 (44.1) vs. 38.1 (26.4) min Duration of event at base, mean (sd): 74.1 (36.1) vs. 77.9 (41.1) vs. 51.2 (26.9) Time, tip rigidity 60–100%, mean (sd): 54.6 (33.4) vs. 58.9 (46.1) vs. 25.2 (22.3) min Duration of event at tip, mean (sd): 67.2 (37.2) vs. 78.9 (42.2) vs. 37.7 (29.8) min Other outcomes assessed: Other RigiScan measures (base and tip RAU, time rigidity of 80–100%, TAU, average event rigidity, average event tumescence) Withdrawals/drop-outs/loss to f/u, n (%): NR WDAE, n (%): NR TAE, n (%): 2 () vs. 1 () vs. 1 () SAE, n (%): 0 Ascertainment of outcomes assessed: RigiScan
Speel (2005) ^264^ Funding source: | N screened = 59 N randomized = 59 IG1, n = 30 CG, n = 29 ITT analysis used for primary outcome: None Inclusion: Patients with complaints of ED and impaired cavernosal perfusion as demonstrated with PPDU. Patients between 35 to 75yrs. Exclusion: Men with penile implants; heart failure or low ejection fraction; uncontrolled hypertension; hypotension; nephropathy or renal artery stenosis; abnormal kidney function; dehydration; taking diuretic; myocardial infraction or stroke within 4 wks; hypersensibility for ACE, participating in any other trial; has medical, psychiatric or substance abuse disorders, hx of malignancy. | Age, mean (sd); 60 (6.8) yrs Race: NR Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C): NR Previous ED treatment: None BMI (kg/m^2^): NR Smoking status: NR Body weight: NR | Concomitant medications: Sildenafil, self - injection with papaverine/ phentolamine prior to sexual intercourse. (70% used) Duration of ED, mean (95% CI) mo IG1: 40 (25–55) CG: 48 (29–67) Underlying disease (diagnosis): n (%) IG1: 9 (30) CG: 3 (10.3) suffered from diabetes Psychogenic ED: None Physiologic ED: None Mixed ED: None | IG1: Quinapril CG: Placebo IG1: Dose: 20mg Duration: 26 – 46 wks Frequency:once a day Compliance (%): (87) CG: Dose: Duration: 26 – 46 wks Frequency: once a day Compliance (%): (93) Run In period: None Wash out period: None F/u duration (on and off treatment): day 14, wk 4, and 2 mo | Primary outcome (EF): Change AT: -13 vs.-18 Change IMT: 0.03 vs. 0.01 Sexual Activity (% change): 8 vs. 20 Severe ED (% change): -32 vs. -35 Other outcomes assessed: IIEF score erection domain (who were sexually active) n (%) >19 (mild): 4 (25) vs. 4 (24) 13–18 (moderate): 7 (44) vs. 6 (35) 5–12 (severe): 5 (31) vs.7 (41) Withdrawals/drop-outs/loss to f/u: n (%). IG1: 2 (6.7) were exclude for lack of compliance. CG: 2 (6.9) Lack of compliance WDAE: n (%). IG1: 2 (6.7) dropped out because of discomfort in the epigastria region. CG: 1 (3.4) had a stroke during study 1 (3.4) died during study because of cerebral hemorrhage. TAE: n (%). IG1: 3 (10) dry cough, 4 (13.3) nausea, 3 (10) joint and muscle pain, and 1 (3.3) twinkle feeling in feet. CG: 2 (6.9) epigastric pain, 1 (3.4) dry cough, 1 (3.4) nausea, 1 (3.4) headache. SAE: n (%). CG: 1 (3.4) had a stroke during study. 1 (3.4) died during study because of cerebral hemorrhage. Ascertainment of outcomes assessed: Cavernosal acceleration time measures during PPDU, IMT, and EF determined by the erection domain of the IIEF questionnaire. (Physician and vascular technologist)
Van Ahlen (1995) ^265^ Funding source: NR | N screened = NR N randomized = 20 IG1 randomized = 20 IG2 randomized = 20 CG randomized = 20 Inclusion: normal results for evaluation of pharmacotesting, evaluation of relevant hormones, pharmaco-Doppler studies and nocturnal penile tumescence Exclusion: severe organic causes of ED, severe cardiac disease, hypertension, DM, elevated liver enzyme concentrations. | Age, mean (sd): 46.3 (±2.7) Race (%): NR Co-morbidities (unrelated to disease): NR Blood glucose (or HbA1C)(%): NR Previous ED treatment: NR BMI (kg/m^2^): NR Smoking status: NR Initial body weight: NR | Concomitant medications: NR Duration of ED (yr) SD: 3.6 (± 0.5) Underlying disease (diagnosis) (N or % of diseased/ grp): NR Psychogenic ED: NR Physiologic ED: NR Mixed ED: NR | IG1: oral naltrexone IG2: oral naltrexone CG: oral placebo IG1: Dose: 25 milligrams (phase 1) Duration: 4wks Frequency: 1×/day Compliance (%): 90 IG2: Dose: 25 milligrams (50 total) Duration: 4wks (phase 2) Frequency: 2×/day Compliance (%): 90 CG: Dose: matching to treatment Duration: 8 wks Frequency: matching IG1 & IG2 Compliance (%): 90 Run In period: 4 wks Wash out period: NR F/u duration (both on and off treatment): NR | Primary outcome results: Intercourse (non-sig), libido (non-sig) Spontaneous early morning erections Baseline: 2.83 ± 0.28 IG1: 4.22 ± 0.31 IG2: 3.78 ± 0.31 List (narrative) other outcomes assessed: None ITT analysis used for primary outcome? NR Withdrawals/drop-outs/loss to f/u [N and or %]: IG1: 1 = psychological reasons IG2: 1= psychological reasons WDAE (N and/or %): 0 TAE: 0 SAE: 0 Ascertainment of outcomes assessed: Daily patient questionnaire, hormonal measurements - no objective evaluations

List of abbreviations: %=percent, ▴=increased, ▾=decreased, AE=adverse event, SAE=serious adverse event, BMI=body mass index, CC=controlled clinical trials, CG=comparator/control group, ctrls=controls, DM=diabetes mellitus, E_1_ IC=intracavernosal injection, ECG=electrocardiograms, ED=erectile dysfunction, EDV=end-diastolic velocity, f/u=follow-up, FMD=flow mediated dilation, GAQ=global assessment question, GEQ=global efficacy question, grp=group/s, HbA1C=haemoglobin, hr=hour(s), hx=history, IG=intervention group, IIEF= international index of erectile function (EF=erectile function, OF=orgasmic function, OS=overall satisfaction, SD=sexual desire), ITT=intent-to-treat (Y = yes, N = no, NR = not reported), IU=intraurethral, kg=kilograms, lbs=pounds, LUTS=lower urinary tract symptoms, M=male, max=maximum, mo=month(s), NA=not applicable, PADAM=partial androgen deficiency of the aging male, PgE_1_=Prostagladin, PRL=prolactin, PSA=prostate-specific antigen, RAU=rigidity activity unit, RCT=randomized control trial, SBP=systolic blood pressure, sign.=significant; TAE=total adverse events, TAU=tumescence activity unit, vs.=versus, WDAE=withdrawals resulting from adverse events, wk=week(s), yr=year(s).

## References

(1) Abdel-Naser MB, Imam A, Wollina U. Sildenafil citrate significantly improves nocturnal penile erections in sildenafil non-responding patients with psychogenic erectile dysfunction. Int J Impot Res. 2004;16(6):552-556. [pmid: 15116063].
(2) Albuquerque DC, Miziara LJ, Saraiva JFK, et al. Efficacy, safety and tolerability of sildenafil in Brazilian hypertensive patients on multiple antihypertensive drugs. Int Braz J Urol. 2005;31(4):342-355. [pmid: 16137403].
(3) Althof SE, O'Leary MP, Cappelleri JC, et al. Self-esteem, confidence, and relationships in men treated with sildenafil citrate for erectile dysfunction: results of two double-blind, placebo-controlled trials. J Gen Intern Med. 2006;21(10):1069-1074. [pmid: 16836626].
(4) Bank AJ, Kelly AS, Kaiser DR, et al. The effects of quinapril and atorvastatin on the responsiveness to sildenafil in men with erectile dysfunction. Vasc Med. 2006;11(4):251-257. [pmid: 17390549].
(5) Bawa AS, Sharma DR, Singh R, et al. Efficacy and tolerability of sildenafil in Indian males with erectile dysfunction: A double-blind, randomized, placebo-controlled, crossover study. Indian J Pharmacol. 2004;36(5):317.
(6) Becher E, Tejada NA, Gomez R, et al. Sildenafil citrate (Viagra) in the treatment of men with erectile dysfunction in southern Latin America: a double-blind, randomized, placebo-controlled, parallel-group, multicenter, flexible-dose escalation study. Int J Impot Res. 2002;14(Suppl 2):33-41.
(7) Boolell M, Gepi-Attee S, Gingell JC, et al. Sildenafil, a novel effective oral therapy for male erectile dysfunction. Br J Urol. 1996;78(2):257-261. [pmid: 8813924].
(8) Boulton AJ, Selam JL, Sweeney M, et al. Sildenafil citrate for the treatment of erectile dysfunction in men with Type II diabetes mellitus. Diabetologia. 2001;44(10):1296-1301. [pmid: 11692178].
(9) Cappelleri JC, Siegel RL, Osterloh IH, et al. Relationship between patient self-assessment of erectile function and the erectile function domain of the international index of erectile function. Urology. 2000;56(3):477-481. [pmid: 10962319].
(10) Lewis R, Bennett CJ, Borkon WD, et al. Patient and partner satisfaction with Viagra (sildenafil citrate) treatment as determined by the Erectile Dysfunction Inventory of Treatment Satisfaction Questionnaire. Urology. 2001;57(5):960-965. [pmid: 11337303].
(11) Cavallini G, Modenini F, Vitali G, et al. Acetyl-L-carnitine plus propionyl-L-carnitine improve efficacy of sildenafil in treatment of erectile dysfunction after bilateral nerve-sparing radical retropubic prostatectomy. Urology. 2005;66(5):1080-1085. [pmid: 16286128].
(12) Chen KK, Hsieh JT, Huang ST, et al. ASSESS-3: a randomised, double-blind, flexible-dose clinical trial of the efficacy and safety of oral sildenafil in the treatment of men with erectile dysfunction in Taiwan. Int J Impot Res. 2001;13(4):221-229. [pmid: 11494079].
(13) Choi HK, Ahn TY, Kim JJ, et al. A double-blind, randomised- placebo, controlled, parallel group, multicentre, flexible-dose escalation study to assess the efficacy and safety of sildenafil administered as required to male outpatients with erectile dysfunction in Korea. Int J Impot Res. 2003;15(2):80-86. [pmid: 12789384].
(14) Choppin A, Blue DR, Hegde SS, et al. Evaluation of oral ro70-0004/003, an alpha1A-adrenoceptor antagonist, in the treatment of male erectile dysfunction. Int J Impot Res. 2001;13(3):157-161. [pmid: 11525314].
(15) Christiansen E, Guirguis WR, Cox D, et al. Long-term efficacy and safety of oral Viagra (sildenafil citrate) in men with erectile dysfunction and the effect of randomised treatment withdrawal. Int J Impot Res. 2000;12(3):177-182. [pmid: 11045912].
(16) DeBusk RF, Pepine CJ, Glasser DB, et al. Efficacy and safety of sildenafil citrate in men with erectile dysfunction and stable coronary artery disease. Am J Cardiol. 2004;93(2):147-153. [pmid: 14715338].
(17) Deveci S, Peskircioglu L, Aygun C, et al. Sublingual sildenafil in the treatment of erectile dysfunction: faster onset of action with less dose. Int J Urol. 2004;11(11):989-992. [pmid: 15509203].
(18) Diamond LE, Earle DC, Garcia WD, et al. Co-administration of low doses of intranasal PT-141, a melanocortin receptor agonist, and sildenafil to men with erectile dysfunction results in an enhanced erectile response. Urology. 2005;65(4):755-759. [pmid: 15833522].
(19) Dinsmore WW, Hodges M, Hargreaves C, et al. Sildenafil citrate (Viagra) in erectile dysfunction: near normalization in men with broad-spectrum erectile dysfunction compared with age-matched healthy control subjects.[erratum appears in Urology 1999 May;53(5):1072]. Urology. 1999;53(4):800-805. [pmid: 10197860].
(20) Dunzendorfer U, Behm A, Dunzendorfer E, et al. Drug combinations in the therapy of low response to phosphodiesterase 5 inhibitors in patients with erectile dysfunction. In Vivo. 2002;16(5):345-348. [pmid: 12494876].
(21) Eardley I, Brooks J, Yates PK, et al. Sildenafil citrate (VIAGRA): an oral treatment for erectile function with activity for up to four hours' duration. Int J Clin Pract. 1999;102(Suppl Jun.):102-104.
(22) Eardley I, Morgan R, Dinsmore W, et al. Efficacy and safety of sildenafil citrate in the treatment of men with mild to moderate erectile dysfunction. Br J Psychiatry. 2001;178(Apr.):325-330. [pmid: 11282811].
(23) Eardley I, Ellis P, Boolell M, et al. Onset and duration of action of sildenafil for the treatment of erectile dysfunction. Br J Clin Pharmacol. 2002;53(Suppl 1):61-65.
(24) Eardley I, Mirone V, Montorsi F, et al. An open-label, multicentre, randomized, crossover study comparing sildenafil citrate and tadalafil for treating erectile dysfunction in men naive to phosphodiesterase 5 inhibitor therapy. BJU Int. 2005;96(9):1323-1332. [pmid: 16287454].
(25) Fava M, Nurnberg HG, Seidman SN, et al. Efficacy and safety of sildenafil in men with serotonergic antidepressant-associated erectile dysfunction: results from a randomized, double-blind, placebo-controlled trial. J Clin Psychiatry. 2006;67(2):240-246. [pmid: 16566619].
(26) Fowler CJ, Miller JR, Sharief MK, et al. A double blind, randomised study of sildenafil citrate for erectile dysfunction in men with multiple sclerosis. J Neurol Neurosurg Psychiatry. 2005;76(5):700-705. [pmid: 15834030].
(27) Gentile V, Vicini P, Prigiotti G, et al. Preliminary observations on the use of propionyl-L-carnitine in combination with sildenafil in patients with erectile dysfunction and diabetes. Curr Med Res Opin. 2004;20(9):1377-1384. [pmid: 15383186].
(28) Gingell C, Sultana SR, Wulff MB, et al. Duration of action of sildenafil citrate in men with erectile dysfunction. J Sex Med. 2004;1(2):179-184. [pmid: 16422972].
(29) Glina S, Bertero E, Claro J, et al. Efficacy and safety of sildenafil citrate for the treatment of erectile dysfunction in Latin America. Braz J Urol. 2001;27(2):148-154.
(30) Glina S, Bertero E, Claro J, et al. Efficacy and safety of flexible-dose oral sildenafil citrate (Viagra) in the treatment of erectile dysfunction in Brazilian and Mexican men. Int J Impot Res. 2002;14(Suppl 2):27-32.
(31) Goldstein I, Lue TF, Padma-Nathan H, et al. Oral sildenafil in the treatment of erectile dysfunction. Sildenafil Study Group. N Engl J Med. 1998;338(20):1397-1404. [pmid: 9580646].
(32) Padma-Nathan H. Oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction: assessment of erections hard enough for sexual intercourse. Int J Clin Pract. 1999;102(Jun.):13-15.
(33) Barry MJ. Sildenafil improved sexual function in erectile dysfunction. Int J Impot Res. 1998;3(6):184.
(34) Gomez F, Davila H, Costa A, et al. Efficacy and safety of oral sildenafil citrate (Viagra) in the treatment of male erectile dysfunction in Colombia, Ecuador, and Venezuela: a double-blind, multicenter, placebo-controlled study. Int J Impot Res. 2002;14(Suppl 2):42-47.
(35) Gopalakrishnan R, Jacob KS, Kuruvilla A, et al. Sildenafil in the treatment of antipsychotic-induced erectile dysfunction: a randomized, double-blind, placebo-controlled, flexible-dose, two-way crossover trial. Am J Psychiatry. 2006;163(3):494-499. [pmid: 16513872].
(36) Hartmann U, Meuleman EJ, Cuzin B, et al. Sildenafil citrate (VIAGRA): analysis of preferred doses in a European, six-month, double-blind, placebo-controlled, flexible dose-escalation study in patients with erectile dysfunction. Multicentre Study Group. Int J Clin Pract. 1999;102(Suppl Jun.):102-109.
(37) Heiman JR, Talley DR, Bailen JL, et al. Sexual function and satisfaction in heterosexual couples when men are administered sildenafil citrate (Viagra) for erectile dysfunction: a multicentre, randomised, double-blind, placebo-controlled trial. BJOG. 2007;114(4):437-447. [pmid: 17284249].
(38) Herrmann HC, Levine LA, Macaluso J Jr, et al. Can atorvastatin improve the response to sildenafil in men with erectile dysfunction not initially responsive to sildenafil? Hypothesis and pilot trial results. J Sex Med. 2006;3(2):303-308. [pmid: 16490024].
(39) Hussain IF, Brady CM, Swinn MJ, et al. Treatment of erectile dysfunction with sildenafil citrate (Viagra) in parkinsonism due to Parkinson's disease or multiple system atrophy with observations on orthostatic hypotension. J Neurol Neurosurg Psychiatry. 2001;71(3):371-374. [pmid: 11511713].
(40) Incrocci L, Koper PC, Hop WC, et al. Sildenafil citrate (Viagra) and erectile dysfunction following external beam radiotherapy for prostate cancer: a randomized, double-blind, placebo-controlled, cross-over study. Int J Radiat Oncol Biol Phys. 2001;51(5):1190-1195. [pmid: 11728676].
(41) Incrocci L, Hop WC, Slob AK. Efficacy of sildenafil in an open-label study as a continuation of a double-blind study in the treatment of erectile dysfunction after radiotherapy for prostate cancer. Urology. 2003;62(1):116-120. [pmid: 12837434].
(42) Kaplan SA, Gonzalez RR, Te AE. Combination of alfuzosin and sildenafil is superior to monotherapy in treating lower urinary tract symptoms and erectile dysfunction. Eur Urol. 2007;51(6):1717-1723. [pmid: 17258855].
(43) Katz SD, Parker JD, Glasser DB, et al. Efficacy and safety of sildenafil citrate in men with erectile dysfunction and chronic heart failure. Am J Cardiol. 2005;95(1):36-42. [pmid: 15619391].
(44) Kongkanand A, Ratana-Olarn K, Ruangdilokrat S, et al. The efficacy and safety of oral sildenafil in Thai men with erectile dysfunction: a randomized, double-blind, placebo controlled, flexible-dose study. J Med Assoc Thai. 2003;86(3):195-205. [pmid: 12757058].
(45) Koulikov D, Fridmans A, Chertin B, et al. Is sildenafil citrate associated with an amelioration of the symptomatology of androgen decline in the aging male?. J Urol. 2007;177(6):2267-2271. [pmid: 17509338].
(46) Levinson IP, Khalaf IM, Shaeer KZ, et al. Efficacy and safety of sildenafil citrate (Viagra) for the treatment of erectile dysfunction in men in Egypt and South Africa. Int J Impot Res. 2003;15(Suppl 1):25-29.
(47) Lindsey I, George B, Kettlewell M, et al. Randomized, double-blind, placebo-controlled trial of sildenafil (Viagra) for erectile dysfunction after rectal excision for cancer and inflammatory bowel disease. Dis Colon Rectum. 2002;45(6):727-732. [pmid: 12072621].
(48) Mahon A, Sidhu PS, Muir G, et al. The efficacy of sildenafil for the treatment of erectile dysfunction in male peritoneal dialysis patients. Am J Kidney Dis. 2005;45(2):381-387. [pmid: 15685517].
(49) McVary KT, Monnig W, Camps JL Jr, et al. Sildenafil citrate improves erectile function and urinary symptoms in men with erectile dysfunction and lower urinary tract symptoms associated with benign prostatic hyperplasia: a randomized, double-blind trial. J Urol. 2007;177(3):1071-1077. [pmid: 17296414].
(50) Melnik T, Abdo CH. Psychogenic erectile dysfunction: comparative study of three therapeutic approaches. J Sex Med. 2005;31(3):243-255.
(51) Meuleman E, Cuzin B, Opsomer RJ, et al. A dose-escalation study to assess the efficacy and safety of sildenafil citrate in men with erectile dysfunction. BJU Int. 2001;87(1):75-81. [pmid: 11121996].
(52) Montorsi F, McDermott TE, Morgan R, et al. Efficacy and safety of fixed-dose oral sildenafil in the treatment of erectile dysfunction of various etiologies. Urology. 1999;53(5):1011-1018. [pmid: 10223498].
(53) Montorsi F, Maga T, Strambi LF, et al. Sildenafil taken at bedtime significantly increases nocturnal erections: results of a placebo-controlled study. Urology. 2000;56(6):906-911. [pmid: 11113728].
(54) Nurnberg HG, Hensley PL, Gelenberg AJ, et al. Treatment of antidepressant-associated sexual dysfunction with sildenafil: a randomized controlled trial. JAMA. 2003;289(1):56-64. [pmid: 12503977].
(55) O'Leary MP, Althof SE, Cappelleri JC, et al. Self-esteem, confidence and relationship satisfaction of men with erectile dysfunction treated with sildenafil citrate: a multicenter, randomized, parallel group, double-blind, placebo controlled study in the United States. J Urol. 2006;175(3 Pt 1):1058-1062. [pmid: 16469617].
(56) Olsson AM, Speakman MJ, Dinsmore WW, et al. Sildenafil citrate (Viagra) is effective and well tolerated for treating erectile dysfunction of psychogenic or mixed aetiology. Int J Clin Pract. 2000;54(9):561-566. [pmid: 11220982].
(57) Olsson AM, Persson CA. Swedish Sildenafil Investigators Group. Efficacy and safety of sildenafil citrate for the treatment of erectile dysfunction in men with cardiovascular disease. Int J Clin Pract. 2001;55(3):171-176. [pmid: 11351770].
(58) Orr G, Weiser M, Polliack M, et al. Effectiveness of sildenafil in treating erectile dysfunction in PTSD patients: a double-blind, placebo-controlled crossover study. J Clin Psychopharmacol. 2006;26(4):426-430. [pmid: 16855464].
(59) Padma-Nathan H, Steers WD, Wicker PA. Efficacy and safety of oral sildenafil in the treatment of erectile dysfunction: a double-blind, placebo-controlled study of 329 patients. Sildenafil Study Group. Int J Clin Pract. 1998;52(6):375-379. [pmid: 9894373].
(60) Padma-Nathan H, Stecher VJ, Sweeney M, et al. Minimal time to successful intercourse after sildenafil citrate: results of a randomized, double-blind, placebo-controlled trial. Urology. 2003;62(3):400-403. [pmid: 12946731].
(61) Palmer JS, Kaplan WE, Firlit CF. Erectile dysfunction in spina bifida is treatable. Lancet. 1999;354(9173):125-126. [pmid: 10408490].
(62) Palmer JS, Kaplan WE, Firlit CF. Erectile dysfunction in patients with spina bifida is a treatable condition. J Urol. 2000;164(3 Pt 2):958-961. [pmid: 10958716].
(63) Perimenis P, Karkoulias K, Markou S, et al. Erectile dysfunction in men with obstructive sleep apnea syndrome: a randomized study of the efficacy of sildenafil and continuous positive airway pressure. Int J Impot Res. 2004;16(3):256-260. [pmid: 15057257].
(64) Perimenis P, Karkoulias K, Konstantinopoulos A, et al. Sildenafil versus continuous positive airway pressure for erectile dysfunction in men with obstructive sleep apnea: a comparative study of their efficacy and safety and the patient's satisfaction with treatment. Asian J Androl. 2007;9(2):259-264. [pmid: 17334593].
(65) Pickering TG, Shepherd AMM, Puddey I, et al. Sildenafil citrate for erectile dysfunction in men receiving multiple antihypertensive agents: A randomized controlled trial. Am J Hypertens. 2004;17(12):1135-1142. [pmid: 15607620].
(66) Price DE, Gingell JC, Gepi-Attee S, et al. Sildenafil: study of a novel oral treatment for erectile dysfunction in diabetic men. Diabet Med. 1998;15(10):821-825. [pmid: 9796881].
(67) Rendell MS, Rajfer J, Wicker PA, et al. Sildenafil for treatment of erectile dysfunction in men with diabetes: a randomized controlled trial. Sildenafil Diabetes Study Group. JAMA. 1999;281(5):421-426. [pmid: 9952201].
(68) Safarinejad MR. Oral sildenafil in the treatment of erectile dysfunction in diabetic men: a randomized double-blind and placebo-controlled study. J Diabetes Complications. 2004;18(4):205-210. [pmid: 15207837].
(69) Safarinejad MR. Salvage of sildenafil failures with cabergoline: a randomized, double-blind, placebo-controlled study. Int J Impot Res. 2006;18(6):550-558. [pmid: 16625231].
(70) Seibel I, Poli de Figueiredo CE, Teloken C, et al. Efficacy of oral sildenafil in hemodialysis patients with erectile dysfunction. J Am Soc Nephrol. 2002;13(11):2770-2775. [pmid: 12397048].
(71) Seidman SN, Roose SP, Menza MA, et al. Treatment of erectile dysfunction in men with depressive symptoms: results of a placebo-controlled trial with sildenafil citrate. Am J Psychiatry. 2001;158(10):1623-1630. [pmid: 11578994].
(72) Rosen RC, Seidman SN, Menza MA, et al. Quality of life, mood, and sexual function: a path analytic model of treatment effects in men with erectile dysfunction and depressive symptoms. Int J Impot Res. 2004;16(4):334-340. [pmid: 14961048].
(73) Shabsigh R. Efficacy of sildenafil citrate (VIAGRA) is not affected by aetiology of erectile dysfunction. Int J Clin Pract. 1999;102(Jun.):19-20.
(74) Sharma RK, Prasad N, Gupta A, et al. Treatment of erectile dysfunction with sildenafil citrate in renal allograft recipients: a randomized, double-blind, placebo-controlled, crossover trial. Am J Kidney Dis. 2006;48(1):128-133. [pmid: 16797395].
(75) Salonia A. Sildenafil citrate: A safe and effective treatment for erectile dysfunction after renal transplantation? Commentary. Nature Clinical Practice Nephrology. 2007;3(2):80-81.
(76) Sommer F, Klotz T, Engelmann U. Improved spontaneous erectile function in men with mild-to-moderate arteriogenic erectile dysfunction treated with a nightly dose of sildenafil for one year: a randomized trial. Asian J Androl. 2007;9(1):134-141. [pmid: 17187165].
(77) Stuckey BG, Jadzinsky MN, Murphy LJ, et al. Sildenafil citrate for treatment of erectile dysfunction in men with type 1 diabetes: results of a randomized controlled trial. Diabetes Care. 2003;26(2):279-284. [pmid: 12547849].
(78) Tan HM, Moh CL, Mendoza JB, et al. Asian sildenafil efficacy and safety study (ASSESS-1): a double-blind, placebo-controlled, flexible-dose study of oral sildenafil in Malaysian, Singaporean, and Filipino men with erectile dysfunction. The Assess-1 Study Group. Urology. 2000;56(4):635-640. [pmid: 11018621].
(79) Lim PH, Ng FC, Cheng CW, et al. Clinical safety profile of sildenafil in Singaporean men with erectile dysfunction: pre-marketing experience (ASSESS-I evaluation). J Int Med Res. 2002;30(2):137-143. [pmid: 12025521].
(80) Tignol J, Furlan PM, Gomez-Beneyto M, et al. Efficacy of sildenafil citrate (Viagra) for the treatment of erectile dysfunction in men in remission from depression. Int Clin Psychopharmacol. 2004;19(4):191-199. [pmid: 15201565].
(81) Ugarte F, Hurtado-Coll A. Comparison of the efficacy and safety of sildenafil citrate (Viagra) and oral phentolamine for the treatment of erectile dysfunction. Int J Impot Res. 2002;14(Suppl 2):48-53.
(82) Webster LJ, Michelakis ED, Davis T, et al. Use of sildenafil for safe improvement of erectile function and quality of life in men with New York Heart Association classes II and III congestive heart failure: a prospective, placebo-controlled, double-blind crossover trial. Arch Intern Med. 2004;164(5):514-520. [pmid: 15006828].
(83) Young JM, Bennett C, Gilhooly P, et al. Efficacy and safety of sildenafil citrate (Viagra) in black and Hispanic American men. Urology. 2002;60(2 Suppl 2):39-48. [pmid: 12414332].
(84) Zinner N. Do food and dose timing affect the efficacy of sildenafil? A randomized placebo-controlled study. J Sex Med. 2007;4(1):137-144. [pmid: 17233779].
(85) Carson CC, Hatzichristou DG, Carrier S, et al. Erectile response with vardenafil in sildenafil nonresponders: a multicentre, double-blind, 12-week, flexible-dose, placebo-controlled erectile dysfunction clinical trial.[erratum appears in BJU Int. 2005 Aug;96(3):466]. BJU Int. 2004;94(9):1301-1309. [pmid: 15610110].
(86) Hatzichristou DG, Aliotta P, Auerbach S, et al. Erectile response to vardenafil in men with a history of nonresponse to sildenafil: A time-from-dosing descriptive analysis. Eur Urol. 2005;27(9):1452-1461.
(87) Demir E, Balal M, Paydas S, et al. Efficacy and safety of vardenafil in renal transplant recipients with erectile dysfunction. Transplant Proc. 2006;38(5):1379-1381. [pmid: 16797309].
(88) Edwards D, Hackett G, Collins O, et al. Vardenafil improves sexual function and treatment satisfaction in couples affected by erectile dysfunction (ED): a randomized, double-blind, placebo-controlled trial in PDE5 inhibitor-naive men with ED and their partners. J Sex Med. 2006;3(6):1028-1036. [pmid: 17100936].
(89) Goldstein I, Young JM, Fischer J, et al. Vardenafil, a new phosphodiesterase type 5 inhibitor, in the treatment of erectile dysfunction in men with diabetes: a multicenter double-blind placebo-controlled fixed-dose study. Diabetes Care. 2003;26(3):777-783. [pmid: 12610037].
(90) Goldstein I, Fisher WA, Sand M, et al. Women's sexual function improves when partners are administered vardenafil for erectile dysfunction: A prospective, randomized, double-blind, placebo-controlled trial. J Sex Med. 2005;2(6):819-832. [pmid: 16422806].
(91) Fisher WA, Rosen RC, Mollen M, et al. Improving the sexual quality of life of couples affected by erectile dysfunction: A double-blind, randomized, placebo-controlled trial of vardenafil. J Sex Med. 2005;2(5):699-708. [pmid: 16422828].
(92) Hatzichristou D, Montorsi F, Buvat J, et al. The efficacy and safety of flexible-dose vardenafil (levitra) in a broad population of European men. Eur Urol. 2004;45(5):634-641. [pmid: 15082207].
(93) Hatzichristou DG, Cuzin B, Martin-Morales A, et al. Vardenafil improves satisfaction rates, depressive symptomatology, and self- confidence in a broad population of men with erectile dysfunction. J Sex Med. 2005;2(1):109-116. [pmid: 16422913].
(94) Hellstrom WJ, Gittelman M, Karlin G, et al. Vardenafil for treatment of men with erectile dysfunction: efficacy and safety in a randomized, double-blind, placebo-controlled trial. J Androl. 2002;23(6):763-771. [pmid: 12399521].
(95) Hellstrom WJ, Elhilali M, Homering M, et al. Vardenafil in patients with erectile dysfunction: achieving treatment optimization. J Androl. 2005;26(5):604-609. [pmid: 16088037].
(96) Donatucci C, Taylor T, Thibonnier M, et al. Verdenafil improves patient satisfaction with erection hardness, orgasmic function and overall sexual experience, while improving quality of life in men with erectile dysfunction. J Sex Med. 2004;1(2):185-192. [pmid: 16422973].
(97) Hellstrom WJ, Gittelman M, Karlin G, et al. Sustained efficacy and tolerability of vardenafil, a highly potent selective phosphodiesterase type 5 inhibitor, in men with erectile dysfunction: results of a randomized, double-blind, 26-week placebo-controlled pivotal trial. Urology. 2003;61(4 Suppl 1):8-14. [pmid: 12657355].
(98) Ishii N, Nagao K, Fujikawa K, et al. Vardenafil 20-mg demonstrated superior efficacy to 10-mg in Japanese men with diabetes mellitus suffering from erectile dysfunction. Int J Urol. 2006;13(8):1066-1072. [pmid: 16903931].
(99) Klotz T, Sachse R, Heidrich A, et al. Vardenafil increases penile rigidity and tumescence in erectile dysfunction patients: a RigiScan and pharmacokinetic study. World J Urol. 2001;19(1):32-39. [pmid: 11289568].
(100) Martin-Morales A, Meijide F, Garcia N, et al. Efficacy of vardenafil and influence on self-esteem and self-confidence in patients with severe erectile dysfunction. J Sex Med. 2007;4(2):440-447. [pmid: 17367439].
(101) Mazo E, Gamidov S, Iremashvili V. The effect of vardenafil on endothelial function of brachial and cavernous arteries. Int J Impot Res. 2006;18(5):464-469. [pmid: 16482199].
(102) Montorsi F, Padma-Nathan H, Buvat J, et al. Earliest time to onset of action leading to successful intercourse with vardenafil determined in an at-home setting: A randomized, double-blind, placebo-controlled trial. J Sex Med. 2004;1(2):168-178. [pmid: 16422971].
(103) Nagao K, Ishii N, Kamidono S, et al. Safety and efficacy of vardenafil in patients with erectile dysfunction: result of a bridging study in Japan. Int J Urol. 2004;11(7):515-524. [pmid: 15242361].
(104) Nehra A, Grantmyre J, Nadel A, et al. Vardenafil improved patient satisfaction with erectile hardness, orgasmic function and sexual experience in men with erectile dysfunction following nerve sparing radical prostatectomy. J Urol. 2005;173(6):2067-2071. [pmid: 15879836].
(105) Brock G, Nehra A, Lipshultz LI, et al. Safety and efficacy of vardenafil for the treatment of men with erectile dysfunction after radical retropubic prostatectomy. J Urol. 2003;170(4 Pt 1):1278-1283. [pmid: 14501741].
(106) Porst H, Rosen R, Padma-Nathan H, et al. The efficacy and tolerability of vardenafil, a new, oral, selective phosphodiesterase type 5 inhibitor, in patients with erectile dysfunction: the first at-home clinical trial. Int J Impot Res. 2001;13(4):192-199. [pmid: 11494074].
(107) Porst H, Young JM, Schmidt AC, et al. Efficacy and tolerability of vardenafil for treatment of erectile dysfunction in patient subgroups. Urology. 2003;62(3):519-523. [pmid: 12946758].
(108) Porst H, Sharlip ID, Hatzichristou D, et al. Extended duration of efficacy of vardenafil when taken 8 hours before intercourse: a randomized, double-blind, placebo-controlled study. Eur Urol. 2006;50(5):1086-1094. [pmid: 16820261].
(109) Rosen R, Shabsigh R, Berber M, et al. Efficacy and tolerability of vardenafil in men with mild depression and erectile dysfunction: The depression-related improvement with vardenafil for erectile response study. Am J Psychiatry. 2006;163(1):79-87. [pmid: 16390893].
(110) Stark S, Sachse R, Liedl T, et al. Vardenafil increases penile rigidity and tumescence in men with erectile dysfunction after a single oral dose. Eur Urol. 2001;40(2):181-188. [pmid: 11528196].
(111) Stief C, Porst H, Saenz dTI, et al. Sustained efficacy and tolerability with vardenafil over 2 years of treatment in men with erectile dysfunction. Int J Clin Pract. 2004;58(3):230-239. [pmid: 15117088].
(112) Valiquette L, Young JM, Moncada I, et al. Sustained efficacy and safety of vardenafil for treatment of erectile dysfunction: a randomized, double-blind, placebo-controlled study. Mayo Clin Proc. 2005;80(10):1291-1297. [pmid: 16212141].
(113) Valiquette L, Montorsi F, Auerbach S, et al. First-dose success with vardenafil in men with erectile dysfunction and associated comorbidities: RELY-I. Int J Clin Pract. 2006;60(11):1378-1385. [pmid: 17073835].
(114) van Ahlen H, Wahle K, Kupper W, et al. Safety and efficacy of vardenafil, a selective phosphodiesterase 5 inhibitor, in patients with erectile dysfunction and arterial hypertension treated with multiple antihypertensives. J Sex Med. 2005;2(6):856-864. [pmid: 16422810].
(115) Ziegler D, Merfort F, Van AH, et al. Efficacy and safety of flexible-dose vardenafil in men with type 1 diabetes and erectile dysfunction. J Sex Med. 2006;3(5):883-891. [pmid: 16942532].
(116) Aversa A, Greco E, Bruzziches R, et al. Relationship between chronic tadalafil administration and improvement of endothelial function in men with erectile dysfunction: a pilot study. Int J Impot Res. 2007;19(2):200-207. [pmid: 16943794].
(117) Carrier S, Brock GB, Pommerville PJ, et al. Efficacy and safety of oral tadalafil in the treatment of men in canada with erectile dysfunction: A randomized, double-blind, parallel, placebo-controlled clinical trial. J Sex Med. 2005;2(5):685-698. [pmid: 16422827].
(118) Carson C, Shabsigh R, Segal S, et al. Efficacy, safety, and treatment satisfaction of tadalafil versus placebo in patients with erectile dysfunction evaluated at tertiary-care academic centers. Urology. 2005;65(2):353-359. [pmid: 15708052].
(119) Chen KK, Jiann BP, Lin JSN, et al. Efficacy and safety of on-demand oral tadalafil in the treatment of men with erectile dysfunction in Taiwan: A randomized, double-blind, parallel, placebo-controlled clinical study. J Sex Med. 2004;1(2):201-208. [pmid: 16422975].
(120) Choi HK, Kim JJ, Kim SC, et al. A randomised, double-blind, parallel, placebo-controlled study of the efficacy and safety of Tadalafil administered on-demand to men with erectile dysfunction in Korea. Taehan Pinyogikwa Hakhoe Chapchi. 2006;47(8):852-858.
(121) De Rose AF, Gallo F, Carmignani G. Evaluation of sexual activity in patients treated with tadalafil: a randomized prospective placebo-controlled trial. Int J Impot Res. 2005;17(1):76-79. [pmid: 15510191].
(122) Eardley I, Gentile V, Austoni E, et al. Efficacy and safety of tadalafil in a Western European population of men with erectile dysfunction. BJU Int. 2004;94(6):871-877. [pmid: 15476525].
(123) Govier F, Potempa AJ, Kaufman J, et al. A multicenter, randomized, double-blind, crossover study of patient preference for tadalafil 20 mg or sildenafil citrate 50 mg during initiation of treatment for erectile dysfunction. Eur Urol. 2003;25(11):2709-2723.
(124) Guo YL, Zhu JC, Pan TM, et al. Efficacy and safety of on-demand tadalafil for the treatment of erectile dysfunction in South-East Asian men. Int J Urol. 2006;13(6):721-727. [pmid: 16834650].
(125) Incrocci L, Slagter C, Slob AK, et al. A randomized, double-blind, placebo-controlled, cross-over study to assess the efficacy of tadalafil (Cialis) in the treatment of erectile dysfunction following three-dimensional conformal external-beam radiotherapy for prostatic carcinoma. Int J Radiat Oncol Biol Phys. 2006;66(2):439-444. [pmid: 16965992].
(126) McMahon CG, Stuckey BG, Lording DW, et al. A 6-month study of the efficacy and safety of tadalafil in the treatment of erectile dysfunction: a randomised, double-blind, parallel-group, placebo-controlled study in Australian men. Int J Clin Pract. 2005;59(2):143-149. [pmid: 15854188].
(127) McMahon C, Kloner RA, Hutter AM Jr, et al. Comparison of efficacy, safety, and tolerability of on-demand tadalafil and daily dosed tadalafil for the treatment of erectile dysfunction. J Sex Med. 2005;2(3):415-427. [pmid: 16422874].
(128) McVary KT, Roehrborn CG, Kaminetsky JC, et al. Tadalafil relieves lower urinary tract symptoms secondary to benign prostatic hyperplasia. J Urol. 2007;177(4):1401-1407. [pmid: 17382741].
(129) Mirone V, Costa P, Damber JE, et al. An evaluation of an alternative dosing regimen with tadalafil, 3 times/week, for men with erectile dysfunction: SURE study in 14 European countries. Eur Urol. 2005;47(6):846-854. [pmid: 15925082].
(130) Moncada I, Damber JE, Mirone V, et al. Sexual intercourse attempt patterns with two dosing regimens of tadalafil in men with erectile dysfunction: Results from the SURE study in 14 European countries. J Sex Med. 2005;2(5):668-674. [pmid: 16422825].
(131) Montorsi F, Nathan HP, McCullough A, et al. Tadalafil in the treatment of erectile dysfunction following bilateral nerve sparing radical retropubic prostatectomy: a randomized, double-blind, placebo controlled trial.[erratum appears in J Urol. 2005 Feb;173(2):664]. J Urol. 2004;172(3):1036-1041. [pmid: 15311032].
(132) Nagao K, Kimoto Y, Marumo K, et al. Efficacy and safety of tadalafil 5, 10, and 20 mg in Japanese men with erectile dysfunction: results of a multicenter, randomized, double-blind, placebo-controlled study. Urology. 2006;68(4):845-851. [pmid: 17070365].
(133) Porst H, Padma-Nathan H, Giuliano F, et al. Efficacy of tadalafil for the treatment of erectile dysfunction at 24 and 36 hours after dosing: a randomized controlled trial. Urology. 2003;62(1):121-125. [pmid: 12837435].
(134) Rajfer J, Aliotta PJ, Steidle CP, et al. Tadalafil dosed once a day in men with erectile dysfunction: a randomized, double-blind, placebo-controlled study in the US. Int J Impot Res. 2007;19(1):95-103. [pmid: 16871272].
(135) Tolra JR, Campana JM, Ciutat LF, et al. Prospective, randomized, open-label, fixed-dose, crossover study to establish preference of patients with erectile dysfunction after taking the three PDE-5 inhibitors. J Sex Med. 2006;3(5):901-909. [pmid: 16942534].
(136) Rosano GM, Aversa A, Vitale C, et al. Chronic treatment with tadalafil improves endothelial function in men with increased cardiovascular risk. Eur Urol. 2005;47(2):214-220. [pmid: 15661417].
(137) Rosen RC, Padma-Nathan H, Shabsigh R, et al. Determining the earliest time within 30 minutes to erectogenic effect after tadalafil 10 and 20 mg: A multicenter, randomized, double-blind, placebo-controlled, at-home study. J Sex Med. 2004;1(2):193-200. [pmid: 16422974].
(138) Saenz dTI, Anglin G, Knight JR, et al. Effects of tadalafil on erectile dysfunction in men with diabetes. Diabetes Care. 2002;25(12):2159-2164. [pmid: 12453954].
(139) Saylan M, Khalaf I, Kadioglu A, et al. Efficacy of tadalafil in Egyptian and Turkish men with erectile dysfunction. Int J Clin Pract. 2006;60(7):812-819. [pmid: 16846400].
(140) Seftel AD, Wilson SK, Knapp PM, et al. The efficacy and safety of tadalafil in United States and Puerto Rican men with erectile dysfunction.[erratum appears in J Urol. 2005 Feb;173(2):664]. J Urol. 2004;172(2):652-657. [pmid: 15247754].
(141) Skoumal R, Chen J, Kula K, et al. Efficacy and treatment satisfaction with on-demand tadalafil (Cialis) in men with erectile dysfunction. Eur Urol. 2004;46(3):362-369. [pmid: 15306109].
(142) Staab A, Tillmann C, Forgue ST, et al. Population dose-response model for tadalafil in the treatment of male erectile dysfunction. Pharm Res. 2004;21(8):1463-1470. [pmid: 15359583].
(143) von Keitz A, Rajfer J, Segal S, et al. A multicenter, randomized, double-blind, crossover study to evaluate patient preference between tadalafil and sildenafil. Eur Urol. 2004;45(4):499-507. [pmid: 15041116].
(144) Yip WC, Chiang HS, Mendoza JB, et al. Efficacy and safety of on demand tadalafil in the treatment of East and Southeast Asian men with erectile dysfunction: a randomized double-blind, parallel, placebo-controlled clinical study. Asian J Androl. 2006;8(6):685-692. [pmid: 16855765].
(145) Young JM, Feldman RA, Auerbach SM, et al. Tadalafil improved erectile function at twenty-four and thirty-six hours after dosing in men with erectile dysfunction: US trial. J Androl. 2005;26(3):310-318. [pmid: 15866997].
(146) Dula E, Keating W, Siami PF, et al. Efficacy and safety of fixed-dose and dose-optimization regimens of sublingual apomorphine versus placebo in men with erectile dysfunction. The Apomorphine Study Group. Urology. 2000;56(1):130-135. [pmid: 10869641].
(147) Dula E, Bukofzer S, Perdok R, et al. Double-blind, crossover comparison of 3 mg apomorphine SL with placebo and with 4 mg apomorphine SL in male erectile dysfunction. Eur Urol. 2001;39(5):558-3. [pmid: 11464037].
(148) Eardley I, Wright P, MacDonagh R, et al. An open-label, randomized, flexible-dose, crossover study to assess the comparative efficacy and safety of sildenafil citrate and apomorphine hydrochloride in men with erectile dysfunction. BJU Int. 2004;93(9):1271-1275. [pmid: 15180621].
(149) Gontero P, D'Antonio R, Pretti G, et al. Clinical efficacy of Apomorphine SL in erectile dysfunction of diabetic men. Int J Impot Res. 2005;17(1):80-85. [pmid: 15510184].
(150) Hagemann JH, Berding G, Bergh S, et al. Effects of visual sexual stimuli and apomorphine SL on cerebral activity in men with erectile dysfunction. Eur Urol. 2003;43(4):412-420. [pmid: 12667723].
(151) Lammers PI, Rubio-Aurioles E, Castell R, et al. Combination therapy for erectile dysfunction: a randomized, double blind, unblinded active-controlled, cross-over study of the pharmacodynamics and safety of combined oral formulations of apomorphine hydrochloride, phentolamine mesylate and papaverine hydrochloride in men with moderate to severe erectile dysfunction. Int J Impot Res. 2002;14(1):54-59. [pmid: 11896479].
(152) Perimenis P, Markou S, Gyftopoulos K, et al. Efficacy of apomorphine and sildenafil in men with nonarteriogenic erectile dysfunction. A comparative crossover study. Andrologia. 2004;36(3):106-110. [pmid: 15206909].
(153) Perimenis P, Gyftopoulos K, Giannitsas K, et al. A comparative, crossover study of the efficacy and safety of sildenafil and apomorphine in men with evidence of arteriogenic erectile dysfunction. Int J Impot Res. 2004;16(1):2-7. [pmid: 14963464].
(154) Porst H, Behre HM, Jungwirth A, et al. Comparative trial of treatment satisfaction, efficacy and tolerability of sildenafil versus apomorphine in erectile dysfunction—an open, randomized cross-over study with flexible dosing. Eur J Med Res. 2007;12(2):61-67. [pmid: 17369119].
(155) von Keitz A, Stroberg P, Bukofzer S, et al. A European multicentre study to evaluate the tolerability of apomorphine sublingual administered in a forced dose-escalation regimen in patients with erectile dysfunction. BJU Int. 2002;89(4):409-415. [pmid: 11872034].
(156) Allen RP, Engel RM, Smolev JK, et al. Objective double-blind evaluation of erectile function with intracorporeal papaverine in combination with phentolamine and/or prostaglandin E1. J Urol. 1992;148(4):1181-1183. [pmid: 1404632].
(157) Aversa A, Rocchietti-March M, Caprio M, et al. Anxiety-induced failure in erectile response to intracorporeal prostaglandin-E1 in non-organic male impotence: a new diagnostic approach. Int J Androl. 1996;19(5):307-313. [pmid: 8985780].
(158) Baum N, Randrup E, Junot D, et al. Prostaglandin E1 versus sex therapy in the management of psychogenic erectile dysfunction. Int J Impot Res. 2000;12(3):191-194. [pmid: 11045914].
(159) Bechara A, Casabe A, Cheliz G, et al. Prostaglandin E1 versus mixture of prostaglandin E1, papaverine and phentolamine in nonresponders to high papaverine plus phentolamine doses. J Urol. 1996;155(3):913-914. [pmid: 8583605].
(160) Bechara A, Casabe A, Cheliz G, et al. Comparative study of papaverine plus phentolamine versus prostaglandin E1 in erectile dysfunction. J Urol. 1997;157(6):2132-2134. [pmid: 9146599].
(161) Buvat J, Costa P, Morlier D, et al. Double-blind multicenter study comparing alprostadil alpha-cyclodextrin with moxisylyte chlorhydrate in patients with chronic erectile dysfunction. J Urol. 1998;159(1):116-119. [pmid: 9400450].
(162) Colli E, Calabro A, Gentile V, et al. Alprostadil sterile powder formulation for intracavernous treatment of erectile dysfunction. Eur Urol. 1996;29(1):59-62. [pmid: 8821692].
(163) Costa P, Sarrazin B, Bressolle F, et al. Efficiency and side effects of intracavernous injections of moxisylyte in impotent patients: a dose-finding study versus placebo. J Urol. 1993;149(2):301-305. [pmid: 8426406].
(164) Dinsmore WW, Gingell C, Hackett G, et al. Treating men with predominantly nonpsychogenic erectile dysfunction with intracavernosal vasoactive intestinal polypeptide and phentolamine mesylate in a novel auto-injector system: a multicentre double-blind placebo-controlled study. BJU Int. 1999;83(3):274-279. [pmid: 10233493].
(165) Earle CM, Keogh EJ, Wisniewski ZS, et al. Prostaglandin E1 therapy for impotence, comparison with papaverine. J Urol. 1990;143(1):57-59. [pmid: 2294263].
(166) el-Saleh JC, Keogh EJ, Chew KK, et al. Does compression of the base of the penis improve the efficacy of intracavernosal injection of prostaglandin E1 for impotence? A randomized controlled study. Int J Impot Res. 1995;7(1):23-31. [pmid: 7670590].
(167) Floth A, Schramek P. Intracavernous injection of prostaglandin E1 in combination with papaverine: enhanced effectiveness in comparison with papaverine plus phentolamine and prostaglandin E1 alone. J Urol. 1991;145(1):56-59. [pmid: 1984099].
(168) Fu Q, Yao DH, Jiang YQ. A clinical comparative study on effects of intracavernous injection of sodium nitroprusside and papaverine/phentolamine in erectile dysfunction patients. Asian J Androl. 2000;2(4):301-303. [pmid: 11202421].
(169) Garceau RJ, Zhang IX, Jen L. Dose-response studies of intracavernous injection therapy with alprostadil in Asian and Australian men with erectile dysfunction. Curr Ther Res Clin Exp. 1996;57(1):50-61.
(170) Gheorghiu D, Godschalk M, Gheorghiu S, et al. Slow injection of prostaglandin E1 decreases associated penile pain. Urology. 1996;47(6):903-904. [pmid: 8677586].
(171) Godschalk MF, Chen J, Katz PG, et al. Treatment of erectile failure with prostaglandin E1: a double-blind, placebo-controlled, dose-response study. J Urol. 1994;151(6):1530-1532. [pmid: 8189563].
(172) Godschalk M, Gheorghiu D, Katz PG, et al. Alkalization does not alleviate penile pain induced by intracavernous injection of prostaglandin E1. J Urol. 1996;156(3):999-1000. [pmid: 8709384].
(173) Gontero P, Fontana F, Bagnasacco A, et al. Is there an optimal time for intracavernous prostaglandin E1 rehabilitation following nonnerve sparing radical prostatectomy? Results from a hemodynamic prospective study. J Urol. 2003;169(6):2166-2169. [pmid: 12771740].
(174) Kattan S, Collins JP, Mohr D. Double-blind, cross-over study comparing prostaglandin E1 and papaverine in patients with vasculogenic impotence. Urology. 1991;37(6):516-518. [pmid: 2038782].
(175) Kattan S. Double-blind randomized crossover study comparing intracorporeal prostaglandin E1 with combination of prostaglandin E1 and lidocaine in the treatment of organic impotence. Urology. 1995;45(6):1032-1036. [pmid: 7771004].
(176) Kunelius P, Lukkarinen O. Intracavernous injection test in the evaluation of patients with erectile dysfunction: a blind, cross-over placebo-controlled study between three different vasoactive agents in 30 impotent inpatients. Sexual Dysfunct. 1998;1(1):35-38.
(177) Linet OI, Ogrinc FG. Efficacy and safety of intracavernosal alprostadil in men with erectile dysfunction. The Alprostadil Study Group. N Engl J Med. 1996;334(14):873-877. [pmid: 8596569].
(178) Mahmoud KZ, el Dakhli MR, Fahmi IM, et al. Comparative value of prostaglandin E1 and papaverine in treatment of erectile failure: double-blind crossover study among Egyptian patients. J Urol. 1992;147(3):623-626. [pmid: 1538443].
(179) Mancini M, Raina R, Agarwal A, et al. Sildenafil citrate vs intracavernous alprostadil for patients with arteriogenic erectile dysfunction: a randomised placebo controlled study. Int J Impot Res. 2004;16(1):8-12. [pmid: 14963465].
(180) Martinez-Pineiro L, Lopez-Tello J, onso Dorrego JM, et al. Preliminary results of a comparative study with intracavernous sodium nitroprusside and prostaglandin E1 in patients with erectile dysfunction. J Urol. 1995;153(5):1487-1490. [pmid: 7714974].
(181) Montorsi F, Guazzoni G, Strambi LF, et al. Recovery of spontaneous erectile function after nerve-sparing radical retropubic prostatectomy with and without early intracavernous injections of alprostadil: results of a prospective, randomized trial. J Urol. 1997;158(4):1408-1410. [pmid: 9302132].
(182) Montorsi F, Guazzoni G, Barbieri L, et al. Genital plus audiovisual sexual stimulation following intracavernous vasoactive injection versus re-dosing for erectile dysfunction—results of a prospective study. J Urol. 1998;159(1):113-115. [pmid: 9400449].
(183) Moriel EZ, Rajfer J. Sodium bicarbonate alleviates penile pain induced by intracavernous injections for erectile dysfunction. J Urol. 1993;149(5 Pt 2):1299-1300. [pmid: 8386779].
(184) Ogrinc FG, Linet OI. Evaluation of real-time RigiScan monitoring in pharmacological erection. J Urol. 1995;154(4):1356-1359. [pmid: 7658536].
(185) Porst H. Prostaglandin E1 and the nitric oxide donor linsidomine for erectile failure: a diagnostic comparative study of 40 patients. J Urol. 1993;149(5 Pt 2):1280-1283. [pmid: 8479015].
(186) Roy JB, Petrone RL, Said SI. A clinical trial of intracavernous vasoactive intestinal peptide to induce penile erection. J Urol. 1990;143(2):302-304. [pmid: 2405186].
(187) Sandhu D, Curless E, Dean J, et al. A double blind, placebo controlled study of intracavernosal vasoactive intestinal polypeptide and phenotolamine mesylate in a novel auto-injector for the treatment of non-psychogenic erectile dysfunction. Int J Impot Res. 1999;11(2):91-97. [pmid: 10356669].
(188) Schramek P, Plas EG, Hubner WA, et al. Intracavernous injection of prostaglandin E1 plus procaine in the treatment of erectile dysfunction. J Urol. 1994;152(4):1108-1110. [pmid: 8072075].
(189) Seyam R, Mohamed K, Akhras AA, et al. A prospective randomized study to optimize the dosage of trimix ingredients and compare its efficacy and safety with prostaglandin E1. Int J Impot Res. 2005;17(4):346-353. [pmid: 15772683].
(190) Soderdahl DW, Thrasher JB, Hansberry KL. Intracavernosal drug-induced erection therapy versus external vacuum devices in the treatment of erectile dysfunction. Br J Urol. 1997;79(6):952-957. [pmid: 9202565].
(191) Sogari PR, Teloken C, Souto CA. Atropine role in the pharmacological erection test: study of 228 patients. J Urol. 1997;158(5):1760-1763. [pmid: 9334595].
(192) Titta M, Tavolini IM, Moro FD, et al. Sexual counseling improved erectile rehabilitation after non-nerve-sparing radical retropubic prostatectomy or cystectomy—results of a randomized prospective study. J Sex Med. 2006;3(2):267-273. [pmid: 16490019].
(193) Van der WF, Dohle GR, Van Der TJ, et al. Intracavernosal injection therapy with and without sexological counselling in men with erectile dysfunction. BJU Int. 2002;89(9):901-904. [pmid: 12010236].
(194) Vanderschueren D, Heyrman RM, Keogh EJ, et al. A study in patients with erectile dysfunction comparing different formulations of prostaglandin E1. Alprostadil Study Group. J Urol. 1995;154(5):1744-1747. [pmid: 7563337].
(195) Viswaroop B, B A, Gopalakrishnan G. Evaluating erectile dysfunction: oral sildenafil versus intracavernosal injection of papaverine. Natl Med J India. 2005;18(6):299-301. [pmid: 16483029].
(196) von Heyden B, Donatucci CF, Marshall GA, et al. A prostaglandin E1 dose-response study in man. J Urol. 1993;150(6):1825-1828. [pmid: 8230515].
(197) Wegner HE, Knispel HH, Klan R, et al. Prostaglandin E1 versus linsidomine chlorhydrate in erectile dysfunction. Urol Int. 1994;53(4):214-216. [pmid: 7855939].
(198) Wegner HE, Knispel HH, Klan R, et al. Efficacy of linsidomine chlorhydrate, a direct nitric oxide donor, in the treatment of human erectile dysfunction: results of a double-blind cross over trial. Int J Impot Res. 1995;7(4):233-237. [pmid: 8770666].
(199) Rosen RC, Diamond LE, Earle DC, et al. Evaluation of the safety, pharmacokinetics and pharmacodynamic effects of subcutaneously administered PT-141, a melanocortin receptor agonist, in healthy male subjects and in patients with an inadequate response to Viagra. Int J Impot Res. 2004;16(2):135-142. [pmid: 14999221].
(200) Segraves RT, Bari M, Segraves K, et al. Effect of apomorphine on penile tumescence in men with psychogenic impotence. J Urol. 1991;145(6):1174-1175. [pmid: 2033687].
(201) Wessells H, Levine N, Hadley ME, et al. Melanocortin receptor agonists, penile erection, and sexual motivation: human studies with Melanotan II. Int J Impot Res. 2000;12(Suppl 4):74-79.
(202) Wessells H, Gralnek D, Dorr R, et al. Effect of an alpha-melanocyte stimulating hormone analog on penile erection and sexual desire in men with organic erectile dysfunction. Urology. 2000;56(4):641-646. [pmid: 11018622].
(203) Ekman P, Sjogren L, Englund G, et al. Optimizing the therapeutic approach of transurethral alprostadil. BJU Int. 2000;86(1):68-74. [pmid: 10886086].
(204) Lazzeri M, Barbanti G, Beneforti P, et al. Intraurethrally infused capsaicin induces penile erection in humans. Scand J Urol Nephrol. 1994;28(4):409-412. [pmid: 7886417].
(205) Padma-Nathan H, Hellstrom WJ, Kaiser FE, et al. Treatment of men with erectile dysfunction with transurethral alprostadil. Medicated Urethral System for Erection (MUSE) Study Group. N Engl J Med. 1997;336(1):1-7. [pmid: 8970933].
(206) Costabile RA, Spevak M, Fishman IJ, et al. Efficacy and safety of transurethral alprostadil in patients with erectile dysfunction following radical prostatectomy. J Urol. 1998;160(4):1325-1328. [pmid: 9751346].
(207) Engel JD, McVary KT. Transurethral alprostadil as therapy for patients who withdrew from or failed prior intracavernous injection therapy. Urology. 1998;51(5):687-692. [pmid: 9610580].
(208) Hellstrom WJ, Bennett AH, Gesundheit N, et al. A double-blind, placebo-controlled evaluation of the erectile response to transurethral alprostadil. Urology. 1996;48(6):851-856. [pmid: 8973666].
(209) Peterson CA, Bennett AH, Hellstrom WJ, et al. Erectile response to transurethral alprostadil, prazosin and alprostadil-prazosin combinations. J Urol. 1998;159(5):1523-1527. [pmid: 9554347].
(210) Shabsigh R, Padma-Nathan H, Gittleman M, et al. Intracavernous alprostadil alfadex is more efficacious, better tolerated, and preferred over intraurethral alprostadil plus optional actis: a comparative, randomized, crossover, multicenter study. Urology. 2000;55(1):109-113. [pmid: 10654905].
(211) Shokeir AA, Alserafi MA, Mutabagani H. Intracavernosal versus intraurethral alprostadil: a prospective randomized study. BJU Int. 1999;83(7):812-815. [pmid: 10368203].
(212) Williams G, Abbou CC, Amar ET, et al. Efficacy and safety of transurethral alprostadil therapy in men with erectile dysfunction. MUSE Study Group. Br J Urol. 1998;81(6):889-894. [pmid: 9666777].
(213) Cavallini G. Minoxidil versus nitroglycerin: a prospective double-blind controlled trial in transcutaneous erection facilitation for organic impotence. J Urol. 1991;146(1):50-53. [pmid: 1905361].
(214) Cavallini G. Minoxidil versus nitroglycerine: a prospective, double-blind, controlled trial in transcutaneous therapy for organic impotence. Int J Impot Res. 1994;6(4):205-212. [pmid: 7795721].
(215) Claes H, Smet G, Baert L. The influence of transcutaneous nitroglycerine on nocturnal erections. J Drug Dev. 1992;4(4):229-233.
(216) Diamond LE, Earle DC, Rosen RC, et al. Double-blind, placebo-controlled evaluation of the safety, pharmacokinetic properties and pharmacodynamic effects of intranasal PT-141, a melanocortin receptor agonist, in healthy males and patients with mild-to-moderate erectile dysfunction. Int J Impot Res. 2004;16(1):51-59. [pmid: 14963471].
(217) Foldvari M, Oguejiofor C, Afridi S, et al. Liposome encapsulated prostaglandin E1 in erectile dysfunction: correlation between in vitro delivery through foreskin and efficacy in patients. Urology. 1998;52(5):838-843. [pmid: 9801110].
(218) Goldstein I, Payton TR, Schechter PJ. A double-blind, placebo-controlled, efficacy and safety study of topical gel formulation of 1% alprostadil (Topiglan) for the in-office treatment of erectile dysfunction. Urology. 2001;57(2):301-305. [pmid: 11182341].
(219) Gomaa A, Shalaby M, Osman M, et al. Topical treatment of erectile dysfunction: randomised double blind placebo controlled trial of cream containing aminophylline, isosorbide dinitrate, and co-dergocrine mesylate. BMJ. 1996;312(7045):1512-1515. [pmid: 8646143].
(220) Gramkow J, Lendorf A, Zhu J, et al. Transcutaneous nitroglycerine in the treatment of erectile dysfunction: a placebo controlled clinical trial. Int J Impot Res. 1999;11(1):35-39. [pmid: 10098952].
(221) Le Roux PJ, Naude JH. Topical vasoactive cream in the treatment of erectile failure: a prospective, randomized placebo-controlled trial. BJU Int. 1999;83(7):810-811. [pmid: 10368202].
(222) Padma-Nathan H, Steidle C, Salem S, et al. The efficacy and safety of a topical alprostadil cream, Alprox-TD, for the treatment of erectile dysfunction: two phase 2 studies in mild-to-moderate and severe ED. Int J Impot Res. 2003;15(1):10-17. [pmid: 12605235].
(223) Padma-Nathan H, Yeager JL. An integrated analysis of alprostadil topical cream for the treatment of erectile dysfunction in 1732 patients. Urology. 2006;68(2):386-391. [pmid: 16904458].
(224) Steidle C, Padma-Nathan H, Salem S, et al. Topical alprostadil cream for the treatment of erectile dysfunction: a combined analysis of the phase II program. Urology. 2002;60(6):1077-1082. [pmid: 12475674].
(225) Yonessi M, Saeedi M. A double-blind placebo-controlled evaluation of the effect of topical sildenafil on erectile dysfunction. J App Res. 2005;5(2):289-294.
(226) Gomaa AA, Hamed HA. Improvement of sexual function in partial testosterone-deficient ageing men treated with cream containing testosterone and vasoactive agents. J Mens Health Gend. 2006;3(1):47-55.
(227) Aversa A, Isidori AM, Spera G, et al. Androgens improve cavernous vasodilation and response to sildenafil in patients with erectile dysfunction. Clin Endocrinol (Oxf). 2003;58(5):632-638. [pmid: 12699447].
(228) Boyanov MA, Boneva Z, Christov VG. Testosterone supplementation in men with type 2 diabetes, visceral obesity and partial androgen deficiency. Aging Male. 2003;6(1):1-7. [pmid: 12809074].
(229) Cavallini G, Caracciolo S, Vitali G, et al. Carnitine versus androgen administration in the treatment of sexual dysfunction, depressed mood, and fatigue associated with male aging. Urology. 2004;63(4):641-646. [pmid: 15072869].
(230) Clopper RR, Voorhess ML, MacGillivray MH, et al. Psychosexual behavior in hypopituitary men: A controlled comparison of gonadotropin and testosterone replacement. Psychoneuroendocrinology. 1993;18(2):149-161. [pmid: 8493299].
(231) Gomaa A, Eissa M, El-Gebaley A. The effect of topically applied vasoactive agents and testosterone versus testosterone in the treatment of erectile dysfunction in aged men with low sexual interest. Int J Impot Res. 2001;13(2):93-99. [pmid: 11426345].
(232) Haren M, Chapman I, Coates P, et al. Effect of 12 month oral testosterone on testosterone deficiency symptoms in symptomatic elderly males with low-normal gonadal status. Age Ageing. 2005;34(2):125-130. [pmid: 15596419].
(233) Kunelius P, Lukkarinen O, Hannuksela ML, et al. The effects of transdermal dihydrotestosterone in the aging male: a prospective, randomized, double blind study. J Clin Endocrinol Metab. 2002;87(4):1467-1472. [pmid: 11932266].
(234) McNicholas TA, Dean JD, Mulder H, et al. A novel testosterone gel formulation normalizes androgen levels in hypogonadal men, with improvements in body composition and sexual function. BJU Int. 2003;91(1):69-74. [pmid: 12614254].
(235) Merza Z, Blumsohn A, Mah PM, et al. Double-blind placebo-controlled study of testosterone patch therapy on bone turnover in men with borderline hypogonadism. Int J Androl. 2006;29(3):381-391. [pmid: 16390499].
(236) Rabkin JG, Wagner GJ, Rabkin R. A double-blind, placebo-controlled trial of testosterone therapy for HIV-positive men with hypogonadal symptoms. Arch Gen Psychiatry. 2000;57(2):141-147. [pmid: 10665616].
(237) Schiavi RC, White D, Mandeli J, et al. Effect of testosterone administration on sexual behavior and mood in men with erectile dysfunction. Arch Sex Behav. 1997;26(3):231-241. [pmid: 9146812].
(238) Rochira V, Balestrieri A, Madeo B, et al. Sildenafil improves sleep-related erections in hypogonadal men: evidence from a randomized, placebo-controlled, crossover study of a synergic role for both testosterone and sildenafil on penile erections.[erratum appears in J Androl. 2006 May-Jun;27(3):480]. J Androl. 2006;27(2):165-175. [pmid: 16278367].
(239) Seftel AD, Mack RJ, Secrest AR, et al. Restorative increases in serum testosterone levels are significantly correlated to improvements in sexual functioning. J Androl. 2004;25(6):963-972. [pmid: 15477371].
(240) Steidle C, Schwartz S, Jacoby K, et al. AA2500 testosterone gel normalizes androgen levels in aging males with improvements in body composition and sexual function. J Clin Endocrinol Metab. 2003;88(6):2673-2681. [pmid: 12788872].
(241) Seidman SN, Roose SP. The sexual effects of testosterone replacement in depressed men: randomized, placebo-controlled clinical trial. J Sex Marital Ther. 2006;32(3):267-273. [pmid: 16809253].
(242) Shabsigh R, Kaufman JM, Steidle C, et al. Randomized study of testosterone gel as adjunctive therapy to sildenafil in hypogonadal men with erectile dysfunction who do not respond to sildenafil alone. J Urol. 2004;172(2):658-663. [pmid: 15247755].
(243) Shamloul R, Ghanem H, Fahmy I, et al. Testosterone therapy can enhance erectile function response to sildenafil in patients with PADAM: A pilot study. J Sex Med. 2005;2(4):559-564. [pmid: 16422854].
(244) Wang C, Swerdloff RS, Iranmanesh A, et al. Transdermal testosterone gel improves sexual function, mood, muscle strength, and body composition parameters in hypogonadal men. J Clin Endocrinol Metab. 2000;85(8):2839-2853. [pmid: 10946892].
(245) Yassin AA, Saad F, Diede HE. Testosterone and erectile function in hypogonadal men unresponsive to tadalafil: results from an open-label uncontrolled study. Andrologia. 2006;38(2):61-68. [pmid: 16529577].
(246) Aydin S, Odabas O, Ercan M, et al. Efficacy of testosterone, trazodone and hypnotic suggestion in the treatment of non-organic male sexual dysfunction. Br J Urol. 1996;77(2):256-260. [pmid: 8800895].
(247) Becker AJ, Stief CG, Machtens S, et al. Oral phentolamine as treatment for erectile dysfunction. J Urol. 1998;159(4):1214-1216. [pmid: 9507837].
(248) Costabile RA, Spevak M. Oral trazodone is not effective therapy for erectile dysfunction: a double-blind, placebo controlled trial. J Urol. 1999;161(6):1819-1822. [pmid: 10332444].
(249) Enzlin P, Vanderschueren D, Bonte L, et al. Trazodone: a double-blind, placebo-controlled, randomized study of its effects in patients with erectile dysfunction without major organic findings. Int J Impot Res. 2000;12(4):223-228. [pmid: 11079363].
(250) Georgitis WJ, Merenich JA. Trial of pentoxifylline for diabetic impotence. Diabetes Care. 1995;18(3):345-352. [pmid: 7555478].
(251) Hatzichristou DG, Apostolidis A, Tzortzis V, et al. Effects of oral phentolamine, taken before sleep, on nocturnal erectile activity: a double-blind, placebo-controlled, crossover study. Int J Impot Res. 2001;13(5):303-308. [pmid: 11890519].
(252) Korenman SG, Viosca SP. Treatment of vasculogenic sexual dysfunction with pentoxifylline. J Am Geriatr Soc. 1993;41(4):363-366. [pmid: 8463520].
(253) Kurt U, Ozkardes H, Altug U, et al. The efficacy of anti-serotoninergic agents in the treatment of erectile dysfunction. J Urol. 1994;152(2 Pt 1):t-9.
(254) Mann K, Pankok J, Leissner J, et al. Effects of moclobemide on sexual performance and nocturnal erections in psychogenic erectile dysfunction. Psychopharmacology. 2001;156(1):86-91. [pmid: 11465638].
(255) Meinhardt W, Schmitz PI, Kropman RF, et al. Trazodone, a double blind trial for treatment of erectile dysfunction. Int J Impot Res. 1997;9(3):163-165. [pmid: 9315494].
(256) Nickel M, Moleda D, Loew T, et al. Cabergoline treatment in men with psychogenic erectile dysfunction: a randomized, double-blind, placebo-controlled study. Int J Impot Res. 2007;19(1):104-107. [pmid: 16728967].
(257) Peskircioglu L, Karabulut A, Deniz E, et al. The role of pentoxifylline in the treatment of erectile dysfunction due to borderline arterial insufficiency. Br J Urol. 1996;77(4):563-565. [pmid: 8777618].
(258) Piha J, Kaaja R. Effects of moxonidine and metoprolol in penile circulation in hypertensive men with erectile dysfunction: Results of a pilot study. Int J Impot Res. 2003;15(4):287-289. [pmid: 12934058].
(259) Reiter WJ, Pycha A, Schatzl G, et al. Dehydroepiandrosterone in the treatment of erectile dysfunction: a prospective, double-blind, randomized, placebo-controlled study. Urology. 1999;53(3):590-594. [pmid: 10096389].
(260) Safarinejad MR. Therapeutic effects of high-dose isoxsuprine in the management of mixed-type impotence. Urology. 2001;58(1):95-97. [pmid: 11445487].
(261) Agostini R, Rossi F, Pajalich R. Myoinositol/folic acid combination for the treatment of erectile dysfunction in type 2 diabetes men: a double-blind, randomized, placebo-controlled study. Eur Rev Med Pharmacol Sci. 2006;10(5):247-250. [pmid: 17121317].
(262) El-Shafey H, Atteya A, el-Magd SA, et al. Tianeptine can be effective in men with depression and erectile dysfunction. J Sex Med. 2006;3(5):910-917. [pmid: 16942535].
(263) Sommer F, Klotz T, Steinritz D, et al. Evaluation of tetrahydrobiopterin (BH4) as a potential therapeutic agent to treat erectile dysfunction. Asian J Androl. 2006;8(2):159-167. [pmid: 16491266].
(264) Speel TGW, Kiemeney LA, Thien T, et al. Long-term effect of inhibition of the angiotensin-converting enzyme (ACE) on cavernosal perfusion in men with atherosclerotic erectile dysfunction: A pilot study. J Sex Med. 2005;2(2):207-212. [pmid: 16422888].
(265) van Ahlen H, Piechota HJ, Kias HJ, et al. Opiate antagonists in erectile dysfunction: a possible new treatment option? Results of a pilot study with naltrexone. Eur Urol. 1995;28(3):246-250. [pmid: 8536780].