# Appendix B. Data Assessment, Data Abstraction and Quality Assessment Forms

To see the Data Assessment, Data Abstraction and Quality Assessment Forms, please select the link below. This link will take you to a PDF of the Forms.

Data Assessment, Data Abstraction and Quality Assessment Forms