# Appendix A. Search Strategies

Medline strategy: [variations of these strategies exist for a) Embase, b) CENTRAL CINAHL AMED, c) Biological abstracts]

## Main Search

OVID MEDLINE Preliminary search

1 Impotence/
2 erectile dysfunction$.mp.
3 1 or 2
4 limit 3 to ebm reviews
5 limit 3 to systematic reviews
6 limit 3 to guideline
7 or/4–6

Diagnostic Questions - Ovid MEDLINE

1 Impotence/
2 erecti$.tw.
3 1 or 2
4 limit 3 to “diagnosis (sensitivity)”
5 routin$.ti.
6 3 and 5
7 or/4,6
8 follicle stimulating hormone/
9 (follicle stimulating hormone or fsh).tw.
10 Luteinizing Hormone/
11 (luteini?ing hormone or lh).tw.
12 Prolactin/
13 prolactin.tw.
14 Testosterone/
15 testosterone.tw.
16 or/8–15
17 7 and 16
18 limit 17 to (yr=“1990 - 2006” and male and english language)
19 limit 18 to (case reports or editorial or letter)
20 18 not 19
21 Impotence/
22 erecti$.tw.
23 21 or 22
24 RANDOMIZED CONTROLLED TRIAL.pt.
25 CONTROLLED CLINICAL TRIAL.pt.
26 RANDOMIZED CONTROLLED TRIALS.sh.
27 RANDOM ALLOCATION.sh.
28 DOUBLE BLIND METHOD.sh.
29 SINGLE-BLIND METHOD.sh.
30 or/24–29
31 (ANIMALS not HUMAN).sh.
32 30 not 31
33 CLINICAL TRIAL.pt.
34 exp CLINICAL TRIALS/
35 (clin$ adj25 trial$).ti,ab.
36 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
37 PLACEBOS.sh.
38 placebo$.ti,ab.
39 random$.ti,ab.
40 versus.tw.
41 RESEARCH DESIGN.sh.
42 or/33–41
43 42 not 31
44 43 not 32
45 32 or 44
46 23 and 45
47 limit 46 to yr=“1990 - 2008”
48 limit 47 to female
49 limit 47 to male
50 47 not (48 not 49)
51 20 not 50
52 limit 51 to english language

OVID EMBASE Diagnostic Questions

1 Erectile Dysfunction/
2 erecti$.tw.
3 1 or 2
4 limit 3 to “diagnosis (sensitivity)”
5 routin$.ti.
6 3 and 5
7 or/4,6
8 follicle stimulating hormone/
9 (follicle stimulating hormone or fsh).tw.
10 Luteinizing Hormone/
11 (luteini?ing hormone or lh).tw.
12 Prolactin/
13 prolactin.tw.
14 Testosterone/
15 testosterone.tw.
16 or/8–15
17 7 and 16
18 limit 17 to (yr=“1990 - 2008” and male and english language)
19 limit 18 to (editorial or letter)
20 18 not 19
21 Erectile Dysfunction/
22 erecti$.tw.
23 21 or 22
24 CLINICAL TRIAL.pt.
25 exp CLINICAL TRIALS/
26 (clin$ adj25 trial$).ti,ab.
27 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
28 PLACEBO.sh.
29 placebo$.ti,ab.
30 random$.ti,ab.
31 versus.tw.
32 METHODOLOGY.sh.
33 or/24–32
34 23 and 33
35 limit 34 to yr=“1990 - 2008”
36 limit 35 to female
37 limit 35 to male
38 35 not (36 not 37)
39 20 not 38

OVID MEDLINE - Intervention questions

1 Impotence/
2 erecti$.tw.
3 1 or 2
4 RANDOMIZED CONTROLLED TRIAL.pt.
5 CONTROLLED CLINICAL TRIAL.pt.
6 RANDOMIZED CONTROLLED TRIALS.sh.
7 RANDOM ALLOCATION.sh.
8 DOUBLE BLIND METHOD.sh.
9 SINGLE-BLIND METHOD.sh.
10 or/4–9
11 (ANIMALS not HUMAN).sh.
12 10 not 11
13 CLINICAL TRIAL.pt.
14 exp CLINICAL TRIALS/
15 (clin$ adj25 trial$).ti,ab.
16 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
17 PLACEBOS.sh.
18 placebo$.ti,ab.
19 random$.ti,ab.
20 versus.tw.
21 RESEARCH DESIGN.sh.
22 or/13–21
23 22 not 11
24 23 not 12
25 12 or 24
26 3 and 25
27 limit 26 to yr=“1990 - 2008”
28 limit 27 to female
29 limit 27 to male
30 27 not (28 not 29)
31 limit 30 to english language

OVID MEDLINE - Intervention questions, Injectable medications

1 Injections/
2 inject$.tw.
3 1 or 2
4 Penis/
5 (peni$ or intercav$).tw.
6 or/4–5
7 3 and 6
8 Papaverine/
9 Phentolamine/
10 Phenoxybenzamine/
11 Alprostadil/
12 Moxisylyte/
13 (papaverine or prostaglandin E1 or PgE1 or phentolamine or phenoxybenzamine or alprostadil or moxisylyte or thymoxamine or Opilon or Icavex or Trimix).tw.
14 or/8–13
15 3 and 14
16 or/7,15
17 Impotence/
18 erectile dysfunction.tw.
19 or/17–18
20 16 and 19
21 limit 20 to (yr=“1990 - 2008” and male and english language)
22 limit 21 to (case reports or comment or editorial)
23 21 not 22

OVID EMBASE - Intervention questions

1 Erectile Dysfunction/
2 erecti$.tw.
3 1 or 2
4 CLINICAL TRIAL.pt.
5 exp CLINICAL TRIALS/
6 (clin$ adj25 trial$).ti,ab.
7 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
8 PLACEBO.sh.
9 placebo$.ti,ab.
10 random$.ti,ab.
11 versus.tw.
12 METHODOLOGY.sh.
13 or/4–12
14 3 and 13
15 limit 14 to yr=“1990 - 2008”
16 limit 15 to female
17 limit 15 to male
18 15 not (16 not 17)
19 limit 18 to english language

OVID EMBASE - Intervention questions - Injectable medications

1 Injection/
2 inject$.tw.
3 1 or 2
4 Penis/
5 (peni$ or intercav$).tw.
6 or/4–5
7 3 and 6
8 Papaverine/
9 Phentolamine/
10 Phenoxybenzamine/
11 Prostaglandin E1/
12 Moxisylyte/
13 (papaverine or prostaglandin E1 or PgE1 or phentolamine or phenoxybenzamine or alprostadil or moxisylyte or thymoxamine or Opilon or Icavex or Trimix).tw.
14 or/8–13
15 3 and 14
16 or/7,15
17 Erectile Dysfunction/
18 erectile dysfunction.tw.
19 or/17–18
20 16 and 19
21 Phenoxybenzamine/ca [Intracavernous Drug Administration]
22 Papaverine/ca
23 Phentolamine/ca
24 Moxisylyte/ca
25 Prostaglandin E1/ca
26 or/21–25
27 26 and 19
28 or/20,27
29 limit 28 to (yr=“1990 - 2008” and male and english language)
30 limit 29 to (editorial or letter or note or short survey)
31 29 not 30

OVID AMED Intervention questions

1 erecti$.mp.
2 impoten$.mp.
3 exp sex disorders male/
4 or/1–3
5 exp clinical trials/
6 random$.mp.
7 or/5–6
8 4 and 7
9 limit 8 to yr=“1990 - 2008”
10 limit 9 to english language

OVID CENTRAL Intervention questions

1 erecti$.mp.
2 impoten$.mp.
3 or/1–2
4 limit 2 to yr=“1990 - 2008”

OVID PsycINFO Intervention questions

1 erecti$.mp.
2 impoten$.mp.
3 impotence/
4 or/1–3
5 exp treatment/
6 random$.tw.
7 control$.tw.
8 placebo$.tw.
9 or/5–8
10 4 and 9
11 limit 10 to yr=“1990 - 2008”
12 limit 11 to female
13 limit 11 to male
14 11 not (12 not 13)
15 limit 14 to english language

Scopus - Intervention questions

(((TITLE-ABS-KEY(placebo) or TITLE-ABS-KEY(clin* W/25 trial*))) OR ((TITLE-ABS-KEY(random*) OR TITLE-ABS-KEY(doubl* w/25 blind*))) OR (TITLE-ABS-KEY(versus))) AND (TITLE-ABS-KEY(erecti*)) AND (LIMIT-TO(PUBYEAR,2006) OR LIMIT-TO(PUBYEAR,1990) OR LIMIT-TO(PUBYEAR,1994) OR LIMIT-TO(PUBYEAR,1998) OR LIMIT-TO(PUBYEAR,1995) OR LIMIT-TO(PUBYEAR,2000) OR LIMIT-TO(PUBYEAR,1992) OR LIMIT-TO(PUBYEAR,2005) OR LIMIT-TO(PUBYEAR,1999) OR LIMIT-TO(PUBYEAR,2001) OR LIMIT-TO(PUBYEAR,1996) OR LIMIT-TO(PUBYEAR,2004) OR LIMIT-TO(PUBYEAR,1991) OR LIMIT-TO(PUBYEAR,1993) OR LIMIT-TO(PUBYEAR,2002) OR LIMIT-TO(PUBYEAR,1997) OR LIMIT-TO(PUBYEAR,2003))

## Vision loss or sleep apnea

Ovid MEDLINE

1 exp Sleep Apnea Syndromes/
2 Optic Neuropathy, Ischemic/
3 exp Vision Disorders/
4 or/1–3
5 (139755-83-2 or 224785-90-4).rn.
6 phosphodiesterase type 5 inhib$.mp.
7 (PDE-5$ or PDE inhibit$).mp.
8 (sildenafil or vardenafil or tadalafil).mp.
9 or/5–8
10 4 and 9

Embase

1 (139755-83-2 or 224785-90-4).rn.
2 phosphodiesterase type 5 inhib$.mp.
3 (PDE-5$ or PDE inhibit$).mp.
4 (sildenafil or vardenafil or tadalafil).mp.
5 or/1–4
6 central sleep apnea syndrome/ or sleep apnea syndrome/
7 ischemic optic neuropathy/ or optic nerve infarction/
8 exp Visual Impairment/
9 or/6–8
10 5 and 9

## Fibrosis secondary to injectable medications

Ovid MEDLINE

1 Injections/
2 inject$.tw.
3 1 or 2
4 Penis/
5 (peni$ or intercav$).tw.
6 or/4–5
7 3 and 6
8 Papaverine/
9 Phentolamine/
10 Phenoxybenzamine/
11 Alprostadil/
12 Moxisylyte/
13 (papaverine or prostaglandin E1 or PgE1 or phentolamine or phenoxybenzamine or alprostadil or moxisylyte or thymoxamine or Opilon or Icavex or Trimix).tw.
14 or/8–13
15 3 and 14
16 or/7,15
17 Penile Induration/
18 Fibrosis/
19 fibro$.tw.
20 or/17–19
21 16 and 20
22 limit 21 to (yr=“1980 - 2006” and english language)

Embase

1 Injections/
2 inject$.tw.
3 1 or 2
4 Penis/
5 (peni$ or intercav$).tw.
6 or/4–5
7 3 and 6
8 Papaverine/
9 Phentolamine/
10 Phenoxybenzamine/
11 Alprostadil/
12 Moxisylyte/
13 (papaverine or prostaglandin E1 or PgE1 or phentolamine or phenoxybenzamine or alprostadil or moxisylyte or thymoxamine or Opilon or Icavex or Trimix).tw.
14 or/8–13
15 3 and 14
16 or/7,15
17 Fibrosis/
18 Peyronie Disease/
19 fibro$.tw.
20 or/17–19
21 16 and 20
22 limit 21 to (yr=“1980 - 2006” and english language)