# List of Acronyms/Abbreviations

CLINICAL
3DCRT | three-dimensional conformal external-beam radiotherapy
AMI | acute myocardial infarction
BMI | body mass index
BPH | benign prostatic hyperplasia
CAD | coronary artery disease
CHF | congestive heart failure
cGMP | cyclic guanosine monophosphate
CI | confidence interval
CRP | C-reactive protein
CT | computer tomography
CVD | cardiovascular disease
DBP | diastolic blood pressure
DM | diabetes mellitus
ECG | electrocardiogram
ED | erectile dysfunction
EDV | end-diastolic velocity
EID | endothelium-independent dilatation
FMD | flow mediated dilation
FSH | follicle-stimulating hormone (pituitary gland)
GnRH | gonadotropin-releasing hormone
HbA1C | hemoglobin,
HDL-c | high-density lipoprotein cholesterol
IC/I | intracavernosal/ injection
IIEF | International Index of Erectile Function
IM/I | intramuscular/ injection
IU | Intraurethral
LDL-c | low-density lipoprotein cholesterol
LH | luteinizing hormone (pituitary gland)
LUTS | lower urinary tract symptoms
MI | myocardial infarction
MuSE | Multiple Streaming Engine (intraurethral pellets of PGE1)
MRI | magnetic resonance imaging
NAION | nonarteritic ischemic optic neuropathy
NO | nitric oxide
nNOS | neuronal nitric oxide synthase
PADAM | partial androgen deficiency of the aging male
PC | prostate cancer
PDE-5/i | phosphodiesterase type 5/ inhibitor
PGE_1_ | prostaglandin E_1_
PH | prostatic hyperplasia
PKG | protein kinase G
PRL | prolactin
PSA | prostate-specific antigen
PSV | peak systolic velocity
RCT | randomized controlled trial
RI | resistance index
RIA | Radioimmunoassay
SBP | systolic blood pressure
SC | Subcutaneous
SD | standard deviation
SE | standard error
T | Testosterone
TG | Triglycerides
TRT | testosterone replacement treatment
WMD | weighted mean difference
Specific Scales (subscales)
AMS | Aging Males Symptoms
CES-D | Center for Epidemiologic Studies Depression Scale
EDITS | Erectile Dysfunction Inventory of Treatment Satisfaction
GAQ | global assessment question
GEQ | global efficacy question
HARS | Hamilton Anxiety Rating Scale
HDRS | Hamilton Depression Rating Scale
IcS | intercourse satisfaction
IIEF | International Index of Erectile Function,
- EF | erectile function
- OF | orgasmic function
- OS | overall satisfaction
- SD | sexual desire
IIEF-5 | modified 5-item IIEF
RAU | rigidity activity unit
SFP | sexual function profile
SHIM | Sexual Health Inventory for Men
TAU | tumescence activity unit
TICS | Trier Inventory for the Assessment of Chronic Stress
UNITS
μg | Micrograms
μg /L | micrograms per liter
μg /mL | micrograms per milliliter
μg/dL | micrograms per deciliter
μm | micromolar
μmol/L | micromoles per liter
cm | centimeters
cm/s | centimeters/second
Ibs | pounds
IU/L | international units per liter
IU/L | international units per liter
kg | kilograms
kg/m2 | kilograms per meter squared
m | meters
mg | milligrams
mg/d | milligrams per day
mL | milliliter
mmol/L | millimoles per liter
N | sample size
ng/dL | nanogram per deciliter
ng/L | nanogram per liter
ng/mL | nanograms per milliliter
nmol/L | nanomoles per liter
pg/mL | picograms per milliliter
pmol/L | picomoles per liter
STATISTICS
ANCOVA | analysis of covariance
ANOVA | analysis of variance
ARD | absolute risk difference
CCT | controlled clinical trial
CI | confidence interval
CV | coefficient of variation
HR | hazard ratio
IQR | interquartile range
ITT | intention to treat
LOCF | last observation carried forward
LS | Least square
NS | not significant
RCT | randomized controlled trial
S/sign. | significant
SD | standard deviation
SE/SEM | standard error
WMD | weighted mean difference
COMMONLY USED ABBREVIATIONS
# | Number
% | Percent
> | greater than
< or </=+ | less than or equal to and
< | less than
> or >/= | greater than or equal to
▴/↑ or ▾/↓ | increased, or decreased,
CG | control group
grp | group/s
ctrls | Controls
d | Day
Deg | Degrees
Dept. | department
F | Female
f/u | followup
FHx | family history
hr | Hour
Hx | History
IG | intervention group
M | Male
max | maximum
min | minimum
mo | Month
NA | not applicable
NIH | National Institute of Health
NR | not reported
prn | pro re nata (as required)
Q | Question
Tx | treatment
versus | Versus
wks | Weeks
y | Year