# Discussion

This evidence report summarized, critically appraised, and compared the evidence on clinical benefits and harms associated with the administration of different types of pharmaceutical agents in the treatment of erectile dysfunction (ED).

## Strength of the Evidence

Erectile dysfunction is a complex condition related to psychosocial and biological factors. It is difficult to reliably document and measure the degree of treatment success in patients diagnosed with this condition. Most of the validated and clinically relevant efficacy outcomes assessed in clinical trials of ED patients are subjective.

The strength of evidence regarding the utility of routine endocrinological blood tests found in this review was limited in terms of the both amount and quality of data. The studies were heterogeneous with respect to patient population characteristics, diagnostic methods, estimates of prevalence, and laboratory methods used (e.g. cut-off values, total, free, or bioavailable hormonal levels).

The placebo-controlled randomized trials that evaluated the efficacy and harms of PDE-5 inhibitors provided large amount of evidence and consistently indicated that patients who received PDE-5 inhibitors experienced greater improvements in erectile dysfunction compared with placebo-treated patients. The magnitude of benefit was clinically relevant and statistically significant. The methodological and reporting quality of the evidence provided by these trials was better than that for other studies (e.g. trials with active control arms or trials evaluating sublingual apomorphine, injections, topical, hormonal, or off-label therapies). Most of these trials enrolled ED patient populations with a broad spectrum of etiologies or comorbidities and assessed the same set of clinically relevant and validated outcome measures. Given the reported exclusion criteria for these trials, their results may not be readily applicable to ED patients with major chronic disorders (e.g. cancer, CVD, diabetes, psychiatric disorders, hepatic or renal diseases) or post-surgery patients, because the magnitude of clinical benefit conferred by PDE-5 inhibitors in such patients is relatively modest. ^384^ – ^386^ Furthermore, vardenafil trials may have been comprised of more responsive patients due to the fact that about half of these trials excluded patients refractory to prior sildenafil therapy, thereby limiting the applicability of the results to a broader population of ED patients. On average, trials that evaluated injected (e.g. intracavernosal, subcutaneous), intra-urethral, topical, or other treatments were of relatively lower methodological and reporting quality.

A common limitation of these trials was a failure to assess and/or report clinically relevant treatment efficacy outcomes used for the measurement of the degree of erectile dysfunction (e.g. mean scores for International Index of Erectile Function, Sexual Encounter Profile, Global Assessment Question regarding improved erection). The most commonly assessed efficacy outcomes in these trials were penile rigidity (using RigiScan) and the quality of erections achieved at home. The trials did not report information on the methods used for randomization, blinding, and allocation concealment. Many study results may have been biased in favor of active treatment, because the analyzed samples predominantly included responders and excluded many randomized participants from their efficacy analyses. There was substantial heterogeneity across the hormonal treatment trials with respect to the diversity of patient populations (variations in inclusion/exclusion criteria; not all patients had ED), treatment interventions (type of intervention, mode of administration, dose, dosing regimen, duration), and the assessed outcomes.

In general, the reporting of harms was less consistent and detailed than that of efficacy outcomes. For example, the occurrence of any or serious adverse events was not reported in many trials. The definition of a serious adverse event may have varied across the trials. Some trials reported only most frequently encountered or treatment-related adverse events, the ascertainment of which may be prone to subjective judgment. In some instances, it was not explicitly defined whether the number and percentage referred to the actual number of adverse events or to the number of patients with at least one adverse event. In open label trials, patients or investigators may have over- or under-reported the incidence of adverse events because of their knowledge of the assigned treatment. Moreover disease-specific complications in patients with comorbidities and/or disorders known to cause ED could have been overlooked. In many cases, the statistical test results for between-group differences in adverse events were not reported, thereby limiting the interpretability of the data.

The reviewed evidence indicated that there is a lack of long-term efficacy and harms data associated with treatments for ED. This is especially important in the case of oral PDE-5 inhibitors and associated harms, given their prevalent use by men in the Western world (e.g. 7 percent of American men aged 56–65 years in 2002). ^30^ Overall, duration of followup for the majority of reviewed trials was not sufficient to permit the reliable assessment of long-term (>6 months) treatment-related outcomes in patients with ED. The duration of followup for many of the PDE-5 inhibitor trials did not exceed 12 weeks. The long-term safety data obtained from retrospective observational studies is not as conclusive as that obtained from well-conducted long-term large randomized trials, which have fewer methodological limitations.

The reviewed evidence consisted of randomized trials using either parallel-arm or crossover design. Although crossover trials are efficient in terms of resources and study power, they require additional caution and careful interpretation of results. For example, one problem inherent in all crossover trials is a potential for a carryover effect, which could be minimized by employing an adequate washout period between alternative treatment periods. ^387^ Although most of the authors reported the duration of washout periods (about 1–2 weeks), it is not clear what minimum length of time would be sufficient to avert or minimize carryover effects from the different types of treatment in patients with ED.

## Question 1: What is the Clinical Utility of Routine Blood Tests—Testosterone, Prolactin, Luteinizing Hormone, Follicle-stimulating Hormone—in Identifying and Affecting Therapeutic Outcomes for Treatable Causes of ED?

The current evidence does not clarify the role of routine hormonal blood tests in all men who present with ED, nor does it clarify whether testing should occur before initiation of a first-line PDE-5 inhibitor treatment versus a more selective approach guided by elevated clinical suspicion for endocrinopathies. The signs and symptoms indicative of hypogonadism may include decreased testes size, alteration in secondary sexual characteristics, decreased libido, changes in mood, a chronic fatigued state or reduced physical performance, as well as altered hematocrit, high- and low-density lipoproteins, or cholesterol. ^388^ Also, it remains unclear whether testing for prolactin, LH, and FSH endocrinopathies is justified as a stand-alone diagnostic strategy if testosterone levels are within the normal limits.

In total, 21 unique studies were reviewed to summarize information needed for determining the clinical utility of routine testosterone, prolactin, luteinizing hormone (LH) and follicle-stimulating hormone (FSH) testing in ED patients. Overall, the heterogeneous nature of the data precludes the reliable evaluation of the utility and limitations of endocrinological testing in the ED population.

### Prevalence of Endocrinological Abnormalities

In the reviewed studies, the prevalence of hypogonadism in the ED population varied widely, with reported rates ranging from 1.72 to 24.1 percent. The total, free and calculated testosterone levels were used as primary measures inconsistently, limiting the ability to meaningfully pool data across studies. The effect of age on the prevalence rates of hypogonadism may not be readily determined. For example, the descriptive analysis did not reveal the patients' age to be an important factor in explaining the observed variation in the prevalence rates of hypogonadism across studies. In contrast, within-study age-stratified results reported for three trials demonstrated that the prevalence rates of hypogonadism (i.e., low free serum testosterone) among men aged 50 years or older were almost doubled compared with the corresponding rates among men below age 50. ^38,^ ^64,^ ^73^ Similarly, there was a wide variation in the prevalence rates of hyperprolactinemia (1.42–14.3 percent). In general, the evidence is inconsistent in indicating what subgroups of ED patients are more likely to have hypogonadism. Very few studies consistently indicated that patients referred to urology clinics for ED who had had decreased libido, testicular damage/abnormality, arterial disease, insulin resistance, or diabetes were more likely to have hypogonadism. The evidence is less consistent with respect to such factors as severity of ED, duration of ED, or sexual disorders (e.g. premature ejaculation).

The wide variation in the prevalence rates of hypogonadism and hyperprolactinemia could be explained by between-study differences in age distribution, types of tests (e.g. measurements of total, free, or bioavailable hormone levels), diagnostic criteria, and many other concurrent conditions that can influence blood testosterone levels.

### Efficacy of Hormonal Treatments

Both studies ^5,^ ^77^ that evaluated efficacy of hormonal treatment compared a combination hormonal treatment (i.e., testosterone gel or patch plus PDE-5 inhibitor) to monotherapy with a PDE-5 inhibitor, and were conducted exclusively in hypogonadal patients refractory to prior PDE-5 treatment. Results from these trials indicated greater improvements in erectile outcomes based on International Index of Erectile Function-Erectile Function domain scores (i.e., erection frequency, erection firmness, penetration ability, and erection confidence), favoring patients who received a combination of testosterone and PDE-5 inhibitors versus those who received PDE-5 inhibitors alone. ^5,^ ^77^ These results warrant a cautious interpretation. For example, one of these trials ^77^ used an open-label design and had low quality methodology and reporting (total Jadad score of 1), thereby limiting the interpretability of the results. These studies were conducted only in ED patients refractory to PDE-5 inhibitor treatments, so the results may not be readily applicable to patients with a partial response or to those naïve to PDE-5 inhibitor treatments. Studies that are more methodologically sound are needed to determine definitively the efficacy of hormonal treatments relative to PDE-5 inhibitors (or any other first-line treatment) in patients with ED and concurrent endocrinological abnormalities.

### Clinical Practice

Evidence regarding accurate identification of men who would benefit from testosterone replacement therapy is scarce. Thus, there is no universally accepted method of identifying men with clinically relevant hypogonadism affecting erectile function and the implications of androgen status for erectile dysfunction and its treatments remains controversial. ^389^ Given the current gaps in knowledge, the most adequate and cost-effective laboratory test for hormonal evaluation is unclear. This problem is reflected in two differing guideline statements. ^14,^ ^39^ The American Urological Association recommends testosterone testing based on initial clinical assessment results or failure of prior management with PDE-5 inhibitors, ^14,^ while the European Urological Association mandates testosterone measures (bioavailable or calculated-free testosterone begin preferred over total levels) for all men with ED. ^39^ These two groups have similar guidelines, which suggest that further endocrinological laboratory investigations including prolactin, LH, and FSH testing are indicated when low testosterone levels are detected. Optimal approaches from a clinical and resource-allocation standpoint remain to be determined. Regardless of the results, clinicians need to direct their initial efforts towards correctly identifying and treating, if possible, an underlying cause of ED, whether it is an endocrine or non-endocrine cause.

## Questions 2–3: What are the Benefits and Harms of Pharmaceutical Treatments for ED? Oral Medications - PDE-5 Inhibitors

### PDE-5 Inhibitors Versus Placebo

Efficacy. Overall, the evidence consistently indicated that patients with ED who received these agents (i.e., sildenafil, vardenafil, or tadalafil), compared with those on placebo, experienced greater improvements in the clinical measures of erectile function such as the mean scores for the International Index of Erectile Function (IIEF) “Erectile Function domain” (i.e., erection frequency, erection firmness, penetration ability, and erection confidence), IIEF-Q3/Q4 (i.e., penetration ability and maintenance frequency), and Sexual Encounter Profile (SEP)-Q2/Q3 (i.e., the per-patient proportion of successful intercourse attempts). The evidence was also consistent in favor of PDE-5 inhibitors over placebo in showing the clinical benefit with respect to the proportion of patients with improved erection (GAQ-Q1). Sildenafil, vardenafil, and tadalafil also demonstrated consistent statistically significant clinical benefits over placebo with regard to mean total scores for the specific IIEF domains such as “Intercourse Satisfaction” (i.e., intercourse frequency, satisfaction, and enjoyment) and “Overall Satisfaction” (i.e., overall satisfaction and relationship satisfaction). Results obtained from the same trials suggested that the effects of sildenafil and tadalafil did not differ from that of placebo for the IIEF domains of “Sexual Desire” (i.e., desire frequency and desire level) and “Orgasmic Function” (ejaculation and orgasm frequency). In a few trials, patients treated with vardenafil had improved in the domains of “Sexual Desire” and/or “Orgasmic Function” compared with placebo-treated patients. ^183,^ ^194,^ ^199,^ ^204^ Furthermore, all trials that reported patient satisfaction with a medication (i.e., mean Erectile Dysfunction Index of Treatment Satisfaction scores) showed statistically significant improved scores for patients who received sildenafil or tadalafil compared with those who received placebo. None of the vardenafil trials reported scores for the Erectile Dysfunction Index of Treatment Satisfaction (EDITS). The results of meta-analyses conducted in this review were consistent with those of qualitative assessments in that they indicate statistically significant improvements in PDE-5 inhibitor-treated (regardless of dose/dosing regimen) patients versus placebo-treated patients with respect to the mean change/endpoint scores of IIEF “EF domain,” IIEF-Q3/Q4, SEP-Q2/Q3, as well as with respect to the proportion of patients with improved erection (GAQ-Q1).

Harms. In general, all three PDE-5 inhibitors were described as well-tolerated drugs whose use was associated with adverse events mainly of a mild or moderate nature. Overall, the occurrence of any all-cause adverse events tended to be higher either numerically or with a statistical significance in patients treated with PDE-5 inhibitors as compared with those treated with placebo. The most commonly observed all-cause adverse events for all three PDE-5 inhibitors were headache, flushing, dyspepsia, and rhinitis. The incidence of serious adverse events was poorly reported. Numerically, there was no obvious imbalance with respect to the occurrence of serious adverse events between patients who received PDE-5 inhibitors and those who received placebo. The result of meta-analysis agreed with those for the qualitative assessment of harms in their indication of an increased risk of any adverse events in patients who received PDE-5 inhibitors (regardless of dose/dosing regimen) compared with those who received placebo.

Two meta-analyses also showed that there were no statistically significant differences with respect to the occurrence of serious adverse events or withdrawals due to adverse events between vardenafil- and placebo-treated groups. Compared with placebo, the use of either sildenafil or vardenafil was associated with an increased risk of either headache or flushing. In addition, patients treated with vardenafil or sildenafil, in comparison with those treated with placebo, were at increased risk of dyspepsia and visual disturbances, respectively.

### Dose-response Effect of PDE-5 Inhibitors

Efficacy. In general, the degree of efficacy in improving erectile function (e.g. scores for the IIEF “EF domain” or individual item scores, SEP-Q2/Q3 scores, percentage of patients who responded “yes” to GAQ-Q1) tended to increase with the doses of PDE-5 inhibitors. The observed trends were either numerical or statistically significant. Formal statistical test results for differences in efficacy between dose-specific arms for PDE-5 inhibitors were not provided in many trial reports, which complicated the interpretation. The observed dose-response trends in efficacy were less obvious for tadalafil trials, in which the degree of improvement in erectile function was numerically similar in patients who received three doses of tadalafil (20 mg, 10 mg, and 5 mg). According to our meta-analyses, in sildenafil trials the proportion of patients with improved erection (GAQ-Q1) was greater for men who received 50 mg compared with those who used a 25 mg dose. The difference for the corresponding proportions between 50 mg and 100 mg groups favored the higher 100 mg dose but was not statistically significant. Although the mean IIEF “EF” domain score and the proportion of “yes” responses to GAQ-Q1 among patients treated with vardenafil favored the 20 mg dose over the 10 mg dose, the differences did not reach the statistical significance.

Harms. The incidence of any all-cause adverse events in sildenafil (25 mg versus 50 mg versus 100 mg) and vardenafil (5 mg versus 10 mg versus 20 mg) trials had a numerical pattern of dose-dependence, indicating that adverse events occurred more frequently at the higher doses. The dose-response pattern for the effect of tadalafil (10 mg versus 20 mg) was not obvious. The meta-analyses conducted on vardenafil trials showed an increased risk of any adverse events in patients treated with the 20 mg versus the 10 mg dose. The difference for the proportion of patients with serious adverse events between the two doses of vardenafil was not statistically significant. Neither the rate of withdrawal resulting from adverse events nor specific adverse events (i.e., headache, flushing, dyspepsia) differed between the two doses. The meta-analyses of sildenafil trials revealed no statistically significant differences in the incidence of specific adverse events (i.e., headache, flushing, or visual disturbances) between the 25 mg, 50 mg, and 100 mg sildenafil groups. The meta-analysis of tadalafil trials found a statistically significant increase in the risk of any adverse events for patients in the 20 mg group relative to those in 10 mg group.

### Dosing Regimens of PDE-5 Inhibitors

Efficacy. Different dosing regimens of PDE-5 inhibitors were evaluated in sildenafil (fixed dose of 50 mg versus flexible dose of 50 mg or 100 mg) ^157^ and tadalafil (20 mg “on demand” versus 20 mg “scheduled”) ^214,^ ^232^ trials. The results of both sildenafil and tadalafil trials indicated no difference in the degree of clinical benefit experienced by patients randomly assigned to different dosing regimens (fixed versus flexible, or “on demand” versus “scheduled”). The benefits were observed for the IIEF “EF” domain or individual item scores, SEP-Q2/Q3 scores, and the percentage who responded “yes” to GAQ-Q1.

Harms. There were no obvious differences in the occurrence of adverse events between “on demand” versus “scheduled” intakes of tadalafil.

### PDE-5 Inhibitors - Mono versus PDE-5 Inhibitors - Combined Therapy

Efficacy. The results suggest that sildenafil used in combination with other therapies may be clinically more beneficial than sildenafil used as monotherapy. In these trials, the administration of sildenafil combination therapies was associated with statistically significant improvements in IIEF “EF” domain and individual IIEF (Q1–Q15) scores as well as in the mean duration of rigidity (≥60 percent) of the penis and the proportion of patients with improved erection (GAQ-Q1), relative to sildenafil monotherapy.

Harms. Based on the limited data from only one trial, ^162^ there was a statistically significant greater proportion of patients with at least one any adverse event (all-cause) in the sildenafil combination therapy (with cabergoline) group compared with the sildenafil monotherapy group. In two trials, ^162,^ ^173^ more patients withdrew due to adverse events in the combined (with either cabergoline or alfuzosin) treatment groups than in the monotherapy groups.

### PDE-5 Inhibitors Versus Other Treatments

Efficacy. Improvements in erectile function (IIEF-“EF domain” scores) observed in 4 head-to-head trials comparing sildenafil, vardenafil, and tadalafil were inconclusive. In these trials, more patients preferred tadalafil over sildenafil or vardenafil. The mean duration from dosing to attempted sexual intercourse was also longer for tadalafil. The patients' preference in favor of tadalafil could partially be explained by a longer acting duration of tadalafil compared with sildenafil or vardenafil observed in these trials. The half-life for tadalafil, sildenafil, and vardenafil is about 17.5 hours, 4 hours, and 4–5 hours, respectively. Furthermore, unlike sildenafil, the absorption of tadalafil is not influenced by food, making it more convenient. ^390,^ ^391^

Compared with other treatments (i.e., continuous positive air pressure [CPAP], phentolamine, alfuzosin, Ro70–0004), sildenafil was shown to be associated with either statistically significant or numerically greater improvements in the mean IIEF “EF” domain and IIEF-Q3/Q4 scores, the rate of improved erections (GAQ-Q1), and the mean duration of rigidity.(>60 percent). ^124,^ ^132,^ ^155,^ ^173^ The four trials comparing sildenafil to apomorphine ^114,^ ^117,^ ^120,^ ^159^ suggest that sildenafil is more effective in improving several outcomes including mean percentage of successful intercourse attempts, mean IIEF scores, and patient satisfaction. Sildenafil had a beneficial clinical effect similar to that of apomorphine in combination with either phentolamine or with phentolamine plus papaverine. ^251^ One explanation for this observed pattern could be that the effect of apomorphine might have been optimized by combining apomorphine with phentolamine alone or also with papaverine.

Harms. The incidence of any adverse events showed no statistically significant difference between patients treated with sildenafil, tadalafil, and vardenafil. ^103,^ ^121,^ ^163^ The limited amount of evidence obtained from one trial ^103^ suggested that groups treated with sildenafil or tadalafil did not differ in the proportion of patients with serious adverse events. In another trial, ^124^ limited data indicated that fewer patients treated with sildenafil had any adverse events (all-cause) or serious adverse events compared with patients treated with phentolamine. Rates of withdrawal due to adverse events were also numerically lower in the sildenafil groups than in either the phentolamine ^124^ or the alfuzosin group. ^173^ The incidence of any adverse events in three trials ^114,^ ^117,^ ^120^ was poorly reported and was numerically greater in patients treated with sildenafil than in those treated with apomorphine. In one trial, ^251^ the proportion of patients with any adverse events was numerically lower in the sildenafil arm compared with the apomorphine combination arms (with phentolamine).

## Sublingual Agents - Apomorphine

### Apomorphine Versus Placebo

Efficacy. Overall, results from the five placebo-controlled trials indicated statistically significant improvements with respect to measures of erectile function (e.g. mean percentage of successful intercourse attempts, percentage of attempts resulting in erections firm enough for intercourse, rigidity ≥40 percent, and the mean IIEF “Erectile Function” domain score) in patients treated with apomorphine compared with those who received placebo. Clinically significant differences were seen in the mean percentage of improved erectile function with apomorphine compared with placebo arms.

Harms. There was insufficient information on the occurrence of any adverse events in these trials to allow comparison of incidence of harms across apomorphine and placebo groups. Adverse events such as nausea, headache, dizziness, and yawning occurred more frequently among patients who received apomorphine than among those who received placebo. The results from two trials suggested that the use of apomorphine was not associated with an increased incidence of any serious adverse events compared with the use of placebo. ^248,^ ^250^

### Dose-response Effect of Apomorphine

Efficacy. Limited evidence from two trials indicated that the mean percentage of successful intercourse attempts did not differ across groups who received various doses of apomorphine treatment (e.g. 3mg, 4 mg, 5 mg, 6 mg, 2–6 mg). This observation suggests that the efficacy of apomorphine may not be dose-related.

Harms. In multiple-dose trials, the occurrence of nausea, yawning, dizziness, vomiting, and glossitis was numerically greater in patients who received higher doses of apomorphine. ^248,^ ^252,^ ^253^

## Intracavernosal Injections

### Prostaglandin E1 (PGE1)

Efficacy. The administration of PGE_1_ was shown to have improved erections more frequently relative to no treatment, placebo, papaverine, moxisylate, linsidomine, sodium nitroprusside, or the combination of linsidomine and urapidil. The rates of improvement in erection for patients receiving PGE_1_, sexual therapy, or the combination of papaverine plus phentolamine were found to be similar. Patients who received PGE_1_ alone experienced rates of improved erection similar to those among patients who received papaverine combined with phentolamine, while improved erection was less frequent after treatment with PGE_1_ plus papaverine. Limited detailed evidence suggests that trimix was at least as effective as PGE_1_ alone. Compared with trimix alone, the combination of trimix and sodium bicarbonate improved erections, while trimix combined with atropine did not produce such benefit. The interpretation of results from trials using trimix is complicated, because concentrations of the three constituents varied from study to study. ^392^

Harms. Penile pain occurred more frequently in patients treated with PGE_1_ than among those treated with placebo, moxisylate, or the combination of papaverine and phentolamine. The pain associated with the treatment was significantly less frequent when the PGE_1_ was injected slowly, or in combination with either lidocaine or procaine, but not when injected in combination with sodium bicarbonate. The combination of papaverine and phentolamine was less frequently associated with pain in comparison with either PGE_1_ alone or PGE_1_ plus papaverine. The treatment with trimix was associated with priapism more frequently relative to treatment with PGE_1_. The variation in rates of priapism may additionally depend on proper testing of the agent in the office setting, dose adjustment process for use at home, teaching sessions during which the patient administers his own injection under supervision, patient compliance, instruction handouts, and/or missed injections.

## Subcutaneous Injections

### Melanotan II, PT-141 (cyclic heptapeptide melanocortin analog), Apomorphine

Efficacy. The trial results indicated greater improvements on RigiScan in patients who received either melanotan II ^295^ or PT-141 ^298^ compared with those who received placebo.

Harms. Although adverse events were generally mild, subcutaneous treatments were associated with an increased risk of nausea and headache in comparison with placebo.

## Intraurethral Suppositories

### Alprostadil

Efficacy. The use of IU alprostadil was shown to be associated with a higher sexual intercourse success rate compared with placebo.

Harms. Patients receiving IU alprostadil had an increased risk of local pain compared with those who received placebo. The followup period of the trials did not exceed 3 months, so the relative benefits and harms of long-term treatment with IU suppositories remain unclear.

## Topical Treatments

### Alprostadil, Nitroglycerine, Aminophylline, Isosorbide Dinitrate, and Co-dergocrine

Efficacy. Although the use of topical alprostadil was associated with improvements in erection and a higher sexual intercourse success rate relative to placebo, the magnitude of this improvement might be small (about 10 percent) and limited to men with mild to moderate ED. Patients who used nitroglycerine plaster before planned intercourse did not have improved erections in comparison with those who used placebo. Nitroglycerine ointment produced only a small improvement in erections. Fewer patients who used nitroglycerine ointment or placebo improved compared with those who took minoxidil. Results for topical aminophylline plus isosorbide dinitrate and co-dergocrine were contradictory, improved erections being found in only one of two trials.

Harms. Adverse events, including local pain, was statistically significantly more frequently in patients treated with topical alprostadil compared with those treated with placebo. Patients who used nitroglycerine plaster before planned intercourse experienced a higher frequency of pain and headaches than those who used placebo. The use of nitroglycerine ointment was associated with increased pain and hypotension.

## Hormonal Treatments

### Testosterone

Efficacy. The effectiveness of testosterone regarding to improve erectile function and sexual intercourse satisfaction was inconsistent compared with placebo. Differences in patient inclusion criteria (e.g. not all trials were comprised of exclusively of ED patients), methods of evaluation, interventions (e.g. mono versus combination treatment, cream, patch, gel, injections), outcome definitions, and use of subjective measures (e.g. IIEF, SEP), could explain some of the discrepancies in results across the studies evaluating the efficacy of testosterone. The intramuscular administration of testosterone was shown to have improved erectile function compared with placebo in only one of four small trials. The “patch” testosterone did not improve sexual function compared with placebo. However, in men with poor response to previous use of sildenafil, testosterone patch plus sildenafil significantly improved the sexual intercourse success rate and satisfaction compared with placebo and sildenafil alone. Gel testosterone (50 mg and 100 mg doses) was found to have increased sexual intercourse frequency compared with placebo. The 100 mg dose of gel testosterone also significantly improved sexual intercourse frequency versus patch testosterone. The use of combination cream of testosterone, isosorbide dinitrate, and co-dergocrine was associated with an increased rate of successful sexual intercourse and improved erections compared with placebo or cream testosterone alone. The application of dihydrotestosterone gel was related to an increased rate of successful sexual intercourse compared with that of placebo.

Although there is insufficient head-to-head data, the gel formulation of testosterone may be a more effective treatment compared with other formulations of testosterone.

Harms. Patients receiving testosterone patch had a higher rate of having application site skin reactions than those with placebo. The use of gel testosterone did not show a dose-related increase in adverse events. The use of combination cream containing testosterone, isosorbide dinitrate, and co-dergocrine was associated with an increased risk of mild headaches compared with placebo or cream testosterone alone. The short-term followup precluded ascertainment of the incidence of prostate cancer. In one trial, ^317^ two patients who had been treated with patch testosterone, developed prostate cancer.

## Other Treatments (Off-label use)

For summary of trials refer to Evidence Table F-10 (Appendix F).

### Phentolamine

Efficacy. The results indicated either numerical or statistically significant improvements in erectile function (i.e., percent of successful intercourse attempts, base/tip rigidity >60 percent for ≥ 10 minutes) were associated with the use of phentolamine relative to placebo. There was no between-group difference for tumescence activity units. ^333^ With insufficient data, statistical test results, and a small number of studies, the trial results are inconclusive regarding the efficacy of phentolamine relative to placebo.

Harms. Due to the lack of sufficient amount of harms data it is not clear if patients taking oral phentolamine are at higher risk of developing adverse events.

### Trazodone

Efficacy. Evidence regarding efficacy of trazodone relative to placebo to treat ED was insufficient (i.e., only 5 smaller-scale trials) and inconsistent. In general, the use of trazodone was not associated with improved erectile function compared with placebo. ^336,^ ^337,^ ^339,^ ^341^ Note that in one trial, ^344^ patients on trazodone experienced statistically significant improvement in erectile response (i.e., at least 3 successful intercourses within 30 days of treatment) compared with those on placebo, ketanserin, or mianserin. Since this trial was not double blind, it is hard to judge if the observed differences were truly due to the treatment administered or to other extraneous factors. The current American Urological Association Practice Guidelines Committee (AUA PGC) does not recommend the use of trazodone in the treatment of ED. ^14^

Harms. Limited evidence suggests that the use of trazodone may be associated with an increased risk of adverse events (priapism, sedation, headache) and higher rates of withdrawal due to adverse events compared with placebo.

### Cabergoline

Efficacy. The limited amount of evidence suggests that the use of cabergoline was associated with numerically or statistically significantly improved mean scores of IIEF “EF” domain and IIEF-Q3/Q4 compared with placebo. Additional evidence from trials using different doses is needed to corroborate or disprove these findings.

Harms. In general, treatment with cabergoline was well tolerated. Nevertheless, there were higher frequencies of adverse events and withdrawals due to adverse events in the active treatment groups than in the placebo groups.

### Pentoxifylline

Efficacy. The results of the trials were inconsistent, one ^340^ indicated statistically significant improvements in peak systolic velocity; and the other trial ^343^ yielded no difference in the frequency of morning erections, nocturnal penile tumescence, or penile rigidity in patients receiving pentoxifylline compared with those on placebo. Another trial ^345^ demonstrated an increased number of successful coital episodes for the active treatment group of patients. However no formal statistical test results were presented to substantiate the findings. Given the above-mentioned limitations, more evidence is needed to draw more definitive conclusions regarding the relative efficacy of pentoxifylline.

Harms. No harms data were reported for two trials. ^343,^ ^345^ Some of the reported treatment-related adverse events in one trial ^340^ were nausea and headache. The harms profile of pentoxifylline in treating ED remains unclear.

### Miscellaneous Agents

Efficacy. Overall, the limited amount of evidence suggested that naltrexone, tianeptine, tetrahydrobiopterin, and dehydroepiandrosterone may be more efficacious than placebo in improving early morning erections, proportion of patients with successful intercourse attempts, duration of rigidity (>60 percent), and mean total IIEF domain-specific scores, respectively. ^342,^ ^348,^ ^352,^ ^353^ The evidence regarding the efficacy of moclobemide, isoxsuprine, angiotensin-converting enzyme (ACE), and myoinositol/folic acid was less conclusive. ^334,^ ^335,^ ^346,^ ^351^ The degree of erectile response was not statistically significantly different for isoxsuprine or ACE relative to placebo. ^335,^ ^346^ Although moxonidine was shown to be more effective in increasing deep penile diameter and artery velocities compared with metoprolol, this result may have been biased because this trial did not employ double blind techniques to adequately mask the treatment modality. ^347^ More trials using a double-blind design are needed to corroborate these findings.

Harms. The limited amount of evidence suggested that the number of patients with adverse events was greater in the treatment groups than in the placebo groups. No definitive conclusions can be made at this time.

## Question 2a-b: Do Specific Patient Characteristics (e.g. Origin, Severity, or Duration of ED, and Comorbid Conditions) Affect Prognosis or Treatment Success for ED Patients?

### Origin of ED

There was a consistent clinical benefit (i.e., IIEF “EF” domain and GAQ-Q1) in patients receiving sildenafil, tadalafil, or vardenafil compared with placebo regardless of their origin of ED (i.e., organic, psychogenic, and mixed). This suggests that quite a broad etiologic spectrum of ED patients could potentially benefit from using these agents to improve the clinical symptoms of ED. This review of evidence did not reveal the presence of any obvious treatment effect modification by the origin of ED. However, these results were obtained from only a few trials, so the evidence warrants a cautious interpretation. Additional trials conducted in these subgroups using uniformly defined clinical outcomes would help to draw more definitive conclusions.

### Baseline Severity of ED

The use of PDE-5 appeared to elicit a better improvement in erectile function (i.e., higher endpoint scores on IIEF “EF domain,” IIEF-Q3/Q4, GAQ-Q1) for patients with mild or moderate baseline severity of ED (IIEF score: 11–25) than for those with severe forms of ED (IIEF score ≤ 10).

### Duration of ED

There is a paucity of evidence on the relative efficacy of PDE-5 inhibitors according to the duration of ED. Only a few trials (i.e., sildenafil versus placebo) reported the efficacy analysis stratified according to the duration of ED with consistent clinical benefits for all patients irrespective of the duration of ED. Furthermore, the two trials in diabetic men with ED ^94,^ ^101^ did not reveal any trends in efficacy (IIEF-Q3/Q4 and GAQ-Q1) across the ED duration strata. The evidence is still inconclusive whether or not the duration of ED is an important prognostic factor for the degree of treatment success (e.g. endpoint IIEF “EF” domain scores, proportion of patients with IIEF >25 at followup).

### Distinct Clinical Subgroups

Evidence on incremental therapeutic benefits associated with the use of PDE-5 inhibitors was consistent across a broad spectrum of patients with ED. The obvious clinical benefit of PDE-5 inhibitors relative to placebo in treating ED was observed not only in the trials that included a broad spectrum of patient population with ED but also in the trials restricted to specific clinically defined homogenous groups of patients with ED (e.g. diabetes, depression, prostate cancer, spina bifida, stable CAD, Parkinson's disease, CHF, LUTS, MS, renal transplants, arterial hypertension, prostatectomy, and no prior treatment for ED). The results of meta-analyses conducted for this review also showed that the use of sildenafil in patients with diabetes, depression, or hypertension led to improvements with respect to IIEF-Q3/Q4, GAQ-Q1, and percentage of successful intercourse attempts.

## Questions 3a: Specific Harms of Pharmaceutical Treatments in Male Patients With ED

### Non-arteritic Anterior Ischemic Optic Neuropathy (NAION) in Men Treated With PDE-5 Inhibitors

This review aimed to search and identify studies reporting the occurrence of Non-Arteritic Anterior Ischemic Optic Neuropathy (NAION) in men treated with sildenafil. Reports included case reports and case series but the absence of denominators precluded the calculation of rates of NAION for sildenafil-exposed versus nonexposed populations. The incidence rates and their ratios (i.e., RRs and 95 percent CIs) for NAION calculated and reported in one cohort study provided inconclusive evidence. Most cases of NAION reported in the reviewed case reports and case series had been treated with 50 mg or higher doses of sildenafil. Moreover, the occurrence of overdose (200 mg) was reported for two NAION cases. The observed trend may suggest potential for an increased risk of NAION in men receiving high doses of sildenafil. Overall, given the insufficient amount and low methodological quality of the identified evidence, it is not clear whether or not men receiving long-term treatment with sildenafil are at increased risk of developing NAION relative to those not receiving this treatment.

### Fibrosis in Men Treated With Injection Treatments

Penile fibrosis, scarring, and indurated nodularity have been reported to be associated with long-term use of ICI with papaverine. There is less data regarding the effect of PGE_1_ on the incidence of penile fibrosis. Penile fibrosis and scarring can lead to abnormal penile curvature with erections and subsequent discontinuation of therapy. ^372^ Since RCTs are of insufficient duration to adequately assess the risk of penile fibrosis, this review evaluated the evidence from 20 retrospective observational studies and clinical trials that reported the incidence of penile fibrosis. The incidence of fibrosis varied widely and was not consistent across studies of treatments with papaverine, triple therapy (Trimix) and PGE_1_. The design of the identified studies and many confounding factors precluded a comparison of the rates of fibrosis between patients receiving injections of PGE1 versus papaverine alone or in combination. The rates of fibrosis may depend on the type and dose of medication, frequency of injections, at home versus office injections, and presence of priapism. ^393,^ ^394^ Evidence regarding the relative incidence of penile fibrosis amongst patients treated with different types of injection therapies is inconclusive. The conduct of well-designed trials is needed to determine the incidence, severity, and health impact of penile fibrosis in long-term ICI users. Moreover, it is important to determine whether there is a medication-, dose- or frequency-response effect of injections. Further evidence is required on whether different injection strategies (e.g. alternating sites) would help to further reduce risk of fibrosis. Penile fibrosis is a complication of ICI and all ED patients receiving this treatment need to be warned of the risk of fibrosis and be examined periodically for fibrotic changes in the penis.

## Methodological and Logistic Limitations of the Systematic Review

This review had methodological and logistic limitations. Some of the important limitations are listed here.

In many cases, the methodological and/or reporting quality of the primary studies was poor, as judged by the Jadad scale and the Schulz allocation concealment component. For example, the adequacy of methods used for randomization, treatment allocation concealment, or blinding could not be ascertained for majority of the reviewed studies. In turn, the absence of this information compromised the valid interpretation of the study results.

There was substantial heterogeneity with respect to efficacy/harms outcomes, types of interventions, diverse concurrent clinical conditions, and reporting quality across the reviewed studies. Clinical and/or methodological heterogeneity limited the extent of statistical pooling of the efficacy- and harms-related data.

In crossover trials, pre-crossover quantitative data was usually not reported making it difficult to incorporate the results into the meta-analyses.

Primary studies did not always provide sufficient quantitative information (e.g. standard deviations, mean endpoint estimates of treatment efficacy, statistical test results) needed to pool the individual trial results and to judge the treatment-related between-group differences in the outcomes. Due to limited resources and the timelines of this review, the authors of individual studies could not be contacted for additional information that was not provided in the reports.

Empirical evidence has shown that harms occurring during a trial are generally underreported. Overall, the occurrence and details of adverse events was poorly reported in the primary studies. Many trial reports did not provide the data on the incidence of any all-cause adverse events and serious adverse events. Moreover, the types of adverse events across the trials, as well as the definition of adverse events and in particular serious adverse events were not reported consistently from study to study. The authors often did not provide statistical test results for the between-group differences in adverse events. Thus, the reviewers resorted solely to qualitative judgment.

This review did not investigate the effectiveness and harms of interventions such as natural health products, vacuum constriction devices, penile prosthesis implants, surgery, or lifestyle modifications. This review also did not include trials in ED patients with spinal cord injury.

The interpretation of the study results was complicated by the lack of well accepted guideline(s) regarding the magnitude of clinically important (or meaningful) difference for a given validated outcome. It is well recognized that the interpretation based solely on the statistical test results may be misleading. The clinically important difference for a valid and relevant outcome may or may not be statistically significant and the opposite also holds true. In many cases, study authors did not report whether the study power to detect a pre-specified minimally relevant clinical difference was estimated.

The evidence needed to evaluate the utility of routine endocrinological testing administered to the ED population is sparse and inconclusive.

## Future Research Recommendations

Efforts are needed to improve the quality of reporting primary studies (i.e., randomized trials). The CONSORT Statement could be considered as a reporting guide for authors reporting trials and journals that publish ED-related research. ^395^

Future studies should focus on both short- and long-term (6 months or longer) clinically relevant valid treatment outcomes. Such studies could clarify important unanswered questions involving both realms of efficacy and harms as well as evaluate relative sustainability of the clinical benefit conferred by different treatment modalities. Additional research should evaluate patient preferences, satisfaction, and compliance with different treatments, including PDE-5 inhibitors. Well designed longer-term RCTs evaluating the effects of PDE-5 inhibitors or other therapies will allow better documentation of the incidence of specific adverse events (e.g. mortality, cardiovascular events, visual disturbances, NAION, penile fibrosis). In light of the presence of comorbidities or causes underlying ED, the comparison of cause-specific therapies (administered alone or in combination) with the first-line treatment(s) in terms of efficacy and safety profiles is warranted. The trials should be more population-based to maximize the degree of external validity of their results.

More trials in clinically homogenous subgroups of ED patients presenting with concomitant conditions (e.g. diabetes, cardiovascular disease, prostate cancer, high blood pressure) are needed to better explore and characterize potential treatment effect modification. Additional investigations of treatment effects in patient subgroups defined by severity, duration, and etiology of ED are also warranted as are therapeutic trials in different ethnic groups of patients with ED.

More efforts are needed to elucidate the minimum clinically important difference (MCID) for the validated and clinically relevant outcomes (e.g. mean scores on IIEF, SEP, proportion of patients with improved erection) for various situations (e.g. patient subgroups, instruments used to measure change in the outcome, self-, partner- or investigator-reported).

Further research is warranted to determine the utility of routine endocrinological blood tests (e.g. serum testosterone, prolactin levels). This would involve studies with large and representative samples of ED patients to estimate precisely the age-stratified prevalence rates for endocrinological abnormalities (e.g. hypogonadism, hyperprolactinemia) and to determine subgroups (or risk factors) of patients with ED who have increased risk of hypogonadism. Ultimately, routine endocrinological blood tests (e.g. total, free, bioavailable) need to be standardized. ^396^

Ideally, studies of testosterone used for the treatment of ED should enroll men with testosterone deficiency. If men with higher testosterone levels are to be included in these trials, stratified analyses should be conducted based on baseline testosterone levels. More data from large trials regarding the safety of long-term use of testosterone therapy is needed for more definitive conclusions.

Future trials of intracavernosal injection treatments should focus on clinically relevant efficacy and harm-related outcomes such as the degree of ED/treatment satisfaction (e.g. scores for International Index of Erectile Function, Erectile Dysfunction Index of Treatment Satisfaction), sexual intercourse success rate (Sexual Encounter Profile scores), penile pain, fibrosis, and priapism. The analyses should include all randomized participants in order to reduce the potential for selection bias (i.e. intention-to-treat analysis).