# Results

## Question 1. What is the Clinical Utility of Routine Blood Tests (Testosterone/Prolactin/Luteinizing Hormone/Follicle-Stimulating Hormone) in Identifying and Affecting Therapeutic Outcomes for Treatable Causes of Erectile Dysfunction (ED)?

## Prevalence of Hormonal Abnormalities in ED Patients

### Literature Search

A total of 22 studies (23 publications) were identified as eligible and were included in the review. ^20,^ ^38,^ ^56^ – ^76^ One study was reported in two publications. ^62,^ ^76^

### Overview of Trials

The prevalence of hypogonadism, hyperprolactinemia, and measurements of serum level LH/FSH were evaluated in 21 ^20,^ ^38,^ ^57^ – ^75^ , 10 ^20,^ ^38,^ ^56,^ ^58,^ ^60,^ ^61,^ ^65,^ ^67,^ ^72,^ ^73^ and 8 ^20,^ ^61,^ ^63^ – ^65,^ ^67,^ ^69,^ ^73^ studies, respectively.

The included studies were conducted in North America, Europe (France, Greece, Spain, Sweden, Turkey, and UK), Brazil, Australia, Egypt, Saudi Arabia, and Malaysia.

The characteristics of included studies are presented in Table 1.

Table 1 Population Characteristics of Studies Measuring Hypogonadism in Men with Erectile Dysfunction

Study details^ 1 ^ | Study Design | Setting | ED Scale | Age | | Comorbidity | Serum Levels | Test time | Cut-off (T) | Normal range(T) | Assay
Mean (SD) | Range
Jaffe 1996 | Prospective | Clinic | NR | 55.3 | | hypertension | TT, BT, PRL, LH, FSH | morning | TT: <3ng/mL BT: <1 ng/ml | NR | RIA
Citron 1996 | Prospective | Endocrinology | NR | 61.2 ±8.9 | 27–79 | Secondary hypogonadism | TT, FT, BT, LH | NR | <2.3 ng/ml | 2.3–9.9 ng/ml | RIA
Hatzichristou 2002 | Prospective | Andrology outpatient clinic | NR | 56 ± 14 | | DM, cardiovascular disease, urinary tract pathology, neurological disease, endocrine pathology | TT, PRL | NR | NR | NR | NR
Martinez-Jabaloyas 2006 | Prospective | Urology clinic | IIEF-EF | 55 ± 10 | | DM, dyslipidemia, hypertension, ischemic cardiopathy | TT, FT, LH, FSH, PRL | morning 8–10 a.m | TT: <2.8 ng/ml FT: <0.228 ng/ml | 2.8–8 ng/mL | NR
Acar 2004 | Prospective | NR | IIEF-5 | 47±10.1 | | chronic disease | TT, PRL, FSH, LH | morning after 8 hours fasting | <3ng/ml (2x) | NS | ECLA
Earle 2003 | Prospective | Department of Endocrinology and Diabetes | NR | 54.9 | 16–82 | NR | TT, PRL LH and FSH if low TT | 1^st^ test NR 2^nd^ test if TT low in first test, taken in the morning | NR | 11–37 nmol/L | RIA
Rhoden 2002 | Prospective | Department of urology, andrology devision | IIEF-5 | 60 | 40–60 | NR | TT | morning 08:00–10:00 | <2.4 ng/mL | 2.4–8.3 ng/mL | RIA
Bunch 2002 | Retrospective | Outpatients | NR | 64.6 ± 10.8 | 51–85 | DM, IHD, hypertension, hyperlipidemia, depression, sleep apnea, CVA, AF, hypothyroidism, prostate cancer, CRF, head tumors, compression fractures | TT, LH | NR | <3 ng/ml | <60: 3–8.9; >60: 2–7.2 ng/ml | RIA
Fahmy 1999 | Prospective | ED clinic | sexual activity questionnaire | NR | | NR | TT, FSH, PRL | morning (9–11 am) | 10 nmol/L | NR | NR
Buvat 1997 | Retrospective | NR | NR | NR | | NR | TT, PRL | morning post 20 min rest | 3 ng/ml (low 2–3; lowest <2) | NR | RIA
Akpunonu 1994 | Prospective | Primary care clinics | NR | 55.4±10 | 24–76 | Renal Failure, DM | TT, PRL, LH, FSH | ns | <10 nmol/L | 10–34.7 nol/L | NR
Drinka 1993 | Prospective | Outpatient department | NR | 71.7 ± 6 | | NR | FT | morning (fasting) | <9 pg/mL | 9–25 pg/ml | RIA
Johnson 1992 | Prospective | Urology clinic | NR | NR | | NR | TT, PRL, LH | NR | <3 ng/dl | 2.2–7.7 ng/dl | RIA
El-Sakka 2005 | Prospective | Endocrinology clinic | IIEF | Endocrinopathy (297) -51.9 ± 12.2 No endocrinopathy (951) -52.3 ± 11.7 | | Obesity, diabetes, hypertension, ischemic heart disease, dyslipidemia, Cerebrovasular stroke | TT, PRL, LH, FSH | morning | <2.8 ng/mL (3x) | 2.8–8.8 ng/mL | ECLA
Tsujimura 2005 | Prospective | Sexual function clinic | AMS, IIEF-5 | 56 (median) | 50–79 | NR | TT, LH, FSH, PRL | Morning 09:00–11:00 | <3.7 ng/mL (11nmol/L) | 2.7–10.7 ng/ml | RIA
Guay 1991 | Prospective | Endocrinology clinic | - | NR | | NR | TT, LH, FSH | morning | NR | TT >3 ng/mL FT 50–200 pg/mL | RIA
Forsberg 1990 | Prospective | Department of urology and clinic for sexual therapy | NR | 47 (median) | | Vascular disease, DM | TT. LH, FSH, PRL | same time of day | Low <10 nmol/L Borderline 10–15 nmol/L | NR | NR
Reyes-Vallejo 2006 | Prospective | NR | NR | 55.2 | 30–79 | Hypercholesterolemia, DM, hypertension, CAD, depression | TT, FT, FSH, LH, PRL | NR | <3 ng/mL | NR | ECLA
El-Sakka 2006 | Prospective | Andrology clinic | IIEF | 53.9 ± 8.5 | 26–86 | overweight, DM, hypertension, IHD, dyslipidemia, psych. Dis. | TT, PRL | morning | <2.8 ng/mL (3x) | 2.8–8.8 ng/mL | ECLA
Hwang 2007 | Prospective | Community | IIEF-5 | NR | | smoking | cFT, TT, BT, FSH, LH, PRL | 9–12 in the morning | ≤11nmol/l | >11nmol/l | NR
Low 2006 | Prospective | Community | IIEF-5 | 59.3 ± 7.38 | | depression | cFT, TT, BT, PRL, LH | before 11 AM | TT: ≤11nmol/l FT: <0.02 nmol/dl BT: <0.2 nmol/dl | NR | direct CMI
Guay 2007 | Retrospective | clinic | SHIM | NR | | DM, metabolic syn., IHD, hyperlipidemia, neurological dys., pelvic surgery | FT | NS | <10 pg/mL | NS | RIA
Zohdy 2007 | Retrospective | NR | IIEF-5 | 40.3 ± 8.9 | 20–56 | NR | TT | morning | <2.8 ng/ml | 2.8–8 ng/mL | ECLA

1 Baseline serum levels: TT = total testosterone; FT = free testosterone; BT: bioavailable testosterone; Pr = prolactin; LH = luteinizing hormone; FSH = folicule-stimulant hormone SD = standard deviation; n = number of events; N = total number of participants; % = prevalence

Assay: chemiluminescent microparticle immunoassay (cmi); electrochemiluminescence immunoassay (ECLA), radioimunoassay (RIA)

* calculated free testosterone

Scales: Sex Health Inventory for Men (SHIM); Sexual Functioning Questionnaire (SFQ); International Index of Erectile Function (IIEF-5) and Aging Males Symptoms (AMS)

### Study and Reporting Quality

The quality of the 22 included studies of men with erectile dysfunction who had their serum levels of testosterone, prolactin, luteinizing hormone (LH) and/or follicle-stimulating hormone (FSH) measured was assessed using QUADAS. ^46^

The QUADAS scores for each study are presented in Table C-2 (Appendix C).

About 60 percent of the studies provided an adequate description of population characteristics and inclusion/exclusion criteria.

### Populations (Studies Reporting on Hypogonadism)

Twenty-one of the included studies measured testosterone serum levels in men with erectile dysfunction as total testosterone (TT) serum levels. ^20,^ ^38,^ ^57^ – ^75^ Two studies reported free testosterone (FT) serum levels, ^59,^ ^66^ two studies reported calculated free testosterone (cFT) serum levels, ^73,^ ^74^ and one study ^73^ calculated bioavailable testosterone (BT) serum levels.

Most studies recruited primary care clinic patients. In 10 studies participants were recruited from specialized clinics (urology, andrology, sexual dysfunction, and endocrinology clinics). Only 11 studies reported the use of a validated questionnaire to measure erectile dysfunction. The participants' mean age across studies ranged from 50 to 60 years. Important comorbidities such as hypertension, diabetes mellitus, and ischemic vascular disease were described in only 8 of the 22 studies.

Further details regarding the serum hormonal level measurements (e.g. time the serum was collected, cut-off values for positive/negative test results) are found in Table 1.

### Prevalence of Hypogonadism (Total Serum Testosterone Levels)

The studies reporting prevalence rates of hypogonadism in ED patients are described in Table 2. All studies included men with a previous diagnosis of erectile dysfunction. The diagnosis of erectile dysfunction was given by a combination of clinical examination and validated questionnaires: the modified 5-item International Index of Erectile Function (IIEF-5) and Aging Males Symptoms (AMS).

Table 2 Prevalence of Hypogonadism in Men with Erectile Dysfunction (serum total testosterone)

Study Details^ 2 ^ | Study Design | Setting | T Mean (SD) | PRL Mean(SD) | LH Mean(SD) | FSH Mean(SD) | Hypogonadism | | | Test time | Cut-off (TT) | Normal Range | Assay
n | N | %
Studies performed in North America
Akpunonu 1994 (USA) | Prospective | Primary care clinics | 14±5.1 nmol/L | 6.3 ± 6.5 mcg/L | 10.6±5.8 IU/L | 14.7±8.6 IU/L | 51 | 212 | 24.1 | NR | <10 nmol/L | 10–34.7 | -
Johnson 1992 (USA) | Prospective | Urology clinic | NR | NR | NR | NR | 7 | 330 | 2.12 | NR | <3 ng/ml | 2.2–7.7 ng/ml | RIA
Citron 1996 (USA) | Prospective* | Endocrinology | 173 ± 44 ng/dl | NR | 5.3±2.8mIU/ml | NR | 11^‡^ | 167 | 6.59 | NR | <2.3 ng/dl | 2.3–9.9 | RIA
Bunch 2002 (USA) | Retrospective* | Out-patients | 177.73 ± 78.36 ng/dL | NR | 6.8±9.1 mIU/ml | NR | 29^‡^ | 201 | 14.42 | NR | <3 ng/dl | 3–8.9 | RIA
Study performed in South America
Rhoden 2002 (Brazil) | Prospective | Department of urology, andrology devision | 530 ± 201 ng/ml | NR | NR | NR | 27 | 520 | 5.19 | morning | <2.4 ng/dl | 2.4–8.3 ng/dl | RIA
Studies performed in Europe
Buvat 1997 (France) | Retrospective | Urology clinic | NR | NR | NR | NR | 68 | 1022 | 6.65 | morning | <3 ng/ml | - | RIA
Hatzichristou 2002 (Greece) | Prospective | Andrology clinic | NR | NR | NR | NR | 22 | 1276 | 1.72 | NR | - | - | -
Martinez-Jabaloyas 2006 (Spain) | Prospective | Urology clinic | 19.6± 7.1 | NR | NR | NR | 8 | 165 | 4.85 | 08:00 – 10:00 in the morning | <2.8 ng/ml | 2.8–8 ng/mL | CMI
Forsberg 1990 (Sweden) | Prospective | Department of urology and clinic for sexual therapy | NR | NR | NR | NR | 13 | 100 | 13.0 | NR | <10 nmol/L | - | -
Fahmy 1999 (UK) | Prospective | ED clinic | NR | NR | NR | NR | 19 | 90 | 21.1 | morning | <10 nmol/L | - | -
Acar 2004 (Turkey) | Prospective | NR | 4.9±1.7 | 10.6 ± 6.4 | 5±3.9 | 6.9±7.7 | 29 | 262 | 11.1 | morning | <3 ng/ml | - | ECLA
Studies performed in Asia and Australia
Earle 2003 (Australia) | Prospective | Department of endocrinology and diabetes | 7.8 (1–10) [101 men with low TT] | 48–7800 μg/L [7 men with hith PRL | 20 (10–56) U/L [18 men with high LH] | NR | 83 | 1455 | 5.70 | 1^st^ test NR 2^nd^ test if TT low in first test, taken in the morning | <11 nmol/l | 12–37 nmol/l | RIA
Tsujimura 2005 (Japan) | Prospective | Sexual function clinic | Low TT (43): 2.2± 0.5 Normal TT (47): 4.5 ± 1.1 | 13.7 ± 15.4 ng/mL | 10.7±9.5 ng/ml | 4.0±2.4 ng/ml | 43 | 90 | 47.7 | morning | <3.17 ng/ml | 2.7–10.7 | RIA
Low 2006 (Malaysia) | Prospective | Primary care | 17.4±6.5 | NR | NR | NR | 49 | 242 | 20.2 | NR | <11 nmol/l | - | CMI
Studies performed in the Middle East
El-Sakka 2005 (Egypt) | Prospective | Andrology clinic | 1.8±0.9 ng/mL | 34 ± 13.9 ng/mL | NR | NR | 187 | 1248 | 15.0 | morning | <2.8 ng/ml | 2.8–8.8 | ECLA
El-Sakka 2006 (Egypt) | Prospective | Andrology clinic | Baseline: 5.1±1.3 Final visit: 3.5 ±1.3 | NS | NR | NR | 16 | 305 | 5.25 | morning | <2.8 ng/ml | 2.8–8.8 | ECLA
Low 2006 (Malaysia) | Prospective | Primary care | 17.37±6.49 nmol/L | NR | NR | NR | 49 | 242 | 20.2 | before 11 AM | ≤11nmol/l | NR | direct chemiluminescent
Zohdy 2007 (Saudi-Arabia) | Retrospective | NR | 3.9±1.7 ng/ml | NR | NR | NR | 54 | 158 | 34.2 | morning | <2.8 ng/ml | 2.8–8.0 | ECLA

2 Baseline serum levels: T = total testosterone; Pr = prolactin; LH = luteinizing hormone; FSH = follicle-stimulating hormone SD = standard deviation; n = number of events; N = total number of participants; % = prevalence

Assay: chemiluminescent microparticle immunoassay (CMI); electrochemiluminescence immunoassay (ECLA), radioimunoassay (RIA)

* All patients in those studies were diagnosed with ED and hypogonadism at baseline;

‡ secondary hypogonadism caused by hypothalamic-pituitary structural abnormalities;

¥ approximately 2/3 of men on this study were using testosterone gel

The prevalence of hypogonadism ranged from 1.72 to 47.7 percent. In one study conducted in Japan, hypogonadism was found in 47.7 percent of the patients. Note that all participants in this study had been diagnosed with partial androgen deficiency of the aging male (PADAM) before entry in the study. ^68^ In one study, ^38^ which reported a prevalence of 6.6 percent, patients had been receiving androgen therapy. In Zohdy et al. 2007 ^75^ all participants presented with obesity and other signs of metabolic syndrome.

In several studies, patients with ED and hypogonadism, who had been referred to urology clinics, were found more likely to have decreased libido, ^20,^ ^38,^ ^67,^ ^72^ testicular damage/abnormality, ^20,^ ^38,^ ^70^ psychological problems with their partner, ^70^ arterial disease, ^70,^ ^72^ obesity, ^67,^ ^75^ hyperlipidemia, ^62^ diabetes, ^62,^ ^72^ or hyperprolactinemia. ^72^

In other studies, patients with hypogonadism did not differ (p-value > 0.05) from eugonadal patients either with respect to age, ^60,^ ^64,^ ^67^ ED severity, ^60,^ ^62,^ ^67^ ED duration, ^60,^ ^67^ the presence of chronic disease, ^60^ smoking, ^60^ loss of libido, ^64^ or premature ejaculation. ^67^ In contrast, one study ^72^ demonstrated that age, ED severity, and longer duration of ED were statistically significant predictors of having hypogonadism in patients with ED.

In two primary care clinic based studies, ^57,^ ^65^ hypogonadal patients were more likely to have higher levels of prolactin ^65^ or hypothalamic abnormalities than those with normal levels of testosterone (21.2 versus 2.9 percent). ^57^

### Prevalence of Hypogonadism (Free Serum Testosterone Levels)

Two studies reported the prevalence of hypogonadism measured by FT (radioimmunoassay, analog method) ^66,^ ^74^ and two studies reported calculated FT levels based on the TT serum levels (Table 3). ^59,^ ^73^

Table 3 Prevalence of Hypogonadism in Men with Erectile Dysfunction (serum free or calculated testosterone)

Study Details^ 3 ^ | Study Design | Setting | T Mean(SD) | PRL Mean(SD) | LH Mean(SD) | FSH Mean(SD) | Hypogonadism | | | Test Time | Cut-off (FT) | Normal Range | Assay
n | N | %
Drinka 1993 (USA) | Prospective | Outpatient department | NR | NR | NR | NR | 6 | 48 | 12.50 | morning (fasting) | <9 pg/mL* | 9–25 pg/ml | RIA (analog)
Guay 2007 (USA) | Prospective | Primary care | With IR - 13 pg/mL No IR - 15.5 pg/mL | NR | NR | NR | 39 | 154 | 25.32 | NR | <10 pg/mL* | - | RIA (analog)
Low 2006 (Malaysia) | Prospective | Community | 0.035 ± 0.012 nmol/L | NR | NR | NR | 38 | 242 | 15.70 | morning (fasting) | <0.0225 nmol/dl* | - | direct CMI
Martinez-Jabaloyas 2006 (Spain) | Prospective | Urology clinic | 0.34± .1 nmol/L | NR | NR | NR | 29 | 165 | 17.58 | morning 8–10 a.m | 0.228 ng/ml* | - | CMI

3 Baseline serum levels: T = total testosterone; Pr = prolactin; LH = luteinizing hormone; FSH = follicle-stimulating hormone SD = standard deviation; n = number of events; N = total number of participants; % = prevalence

Assay: chemiluminescent microparticle immunoassay (cmi); electrochemiluminescence immunoassay (ECLA), radioimunoassay (RIA)

* calculated free testosterone

The prevalence of hypogonadism using FT serum levels (radioimmunoassay, analog method) across these studies varied from 12.5 to 25.32 percent. The corresponding range for the prevalence of hypogonadism using calculated-free testosterone serum levels was 15.7 to 17.58 percent.

One study, ^74^ found a statistically significant association between hypogonadism and insulin resistance by showing a higher proportion of patients with insulin resistance amongst hypogonadal versus eugonadal patients (92.3 versus 25.2 percent, p value= 0.02).

### Prevalence of Hypogonadism (Bioavailable Serum Testosterone Levels)

Serum Bio-T levels were reported in one study. ^73^ , where the prevalence of hypogonadism was 0.41 percent and the average level of Bio-T was 0.84 ± 0.28 nmol/L. (Table 4).

Table 4 Prevalence of Hypogonadism in Men with Erectile Dysfunction (serum bioavailable testosterone)

Study Details^ 4 ^ | Study Design | Setting | T Mean(SD) | PRL Mean(SD) | LH Mean(SD) | FSH Mean(SD) | Hypogonadism | | | Test time | Cut-off (FT) | Normal Range | Assay
n | N | %
Low 2006 (Malaysia) | Prospective | Community | 0.84 ± 0.28 nmol/L | NR | NR | NR | 1 | 242 | 0.41 | morning (fasting) | <0.2 nmol/dl | - | direct CMI

4 Baseline serum levels: T = total testosterone; Pr = prolactin; LH = luteinizing hormone; FSH = follicle-stimulating hormone SD = standard deviation; n = number of events; N = total number of participants; % = prevalence

Assay: chemiluminescent microparticle immunoassay (cmi); electrochemiluminescence immunoassay (ECLA), radioimunoassay (RIA)

* calculated free testosterone

### Populations (Studies Reporting on Hyperprolactinemia)

Ten studies measured prolactin serum levels in men with ED to detect hyperprolactinemia. ^20,^ ^38,^ ^56,^ ^58,^ ^60,^ ^61,^ ^65,^ ^67,^ ^72,^ ^73^ Patients were recruited from primary care clinics ^56,^ ^65,^ ^73^ or from specialized clinics (urology, andrology, and endocrinology). ^20,^ ^38,^ ^58,^ ^61,^ ^67,^ ^72^ The mean age of participants ranged from 47 to 59 years. Only five studies reported important comorbidities, such as hypertension, diabetes mellitus, and ischemic vascular disease. Further details on these studies are provided in Table 5.

Table 5 Population Characteristics of Studies Measuring Hyperprolactinemia in Men with Erectile Dysfunction

Study Details^ 5 ^ | Study Design | Setting | ED Scale | Age | | Comorbidity | Serum levels | Test time | Cut-off (PRL) | Normal Range (PRL) | Assay
Mean | (SD) Range
Jaffe 1996 (Israel) | Prospective | Outpatient clinic | NR | 55.3 | | hypertension | TT, BT, PRL, LH, FSH | at least 2hrs post awakening | >20 ng/ml | NR | EIA
Netto 1993 (Brazil) | Prospective | Outpatient clinic | NR | 55 | 31–69 | NR | PRL | morning | 20 ng/ml | NR | RIA
Hatzichristou 2002 (Greece) | Prospective | Andrology outpatient clinic | NR | 56 ± 14 | | DM, cardiovascular disease, urinary tract pathology, neurological disease, endocrine pathology | TT, PRL | NR | NR | NR | NR
Acar 2004 Turkey) | Prospective | NR | IIEF-5 | 47±10.1 | | chronic disease | TT, PRL, LH, FSH | morning after 8 hours fasting | >18ng/ml (2x) | NR | ECLA
Earle 2003 (Australia) | Prospective | Department of endocrinology and diabetes | NR | 54.9 | 16–82 | NR | TT, PRL LH and FSH if low TT | morning^‡^ | ≥25 mcg/L | <25 mcg/L | RIA
Buvat 1997 (France) | Prospective | Urology clinic | NR | NR | | NR | TT, PRL | morning post 20 min rest | 20 ng/ml (high 20–35; highest >35) | NR | RIA
Akpunonu 1994 (USA) | Prospective | Primary care clinic | NR | 55.4±10 | 24–76 | Renal failure, DM | TT, PRL, LH, FSH | NR | >20 mcg/l | 0–20 mcg/l | NS
Johnson 1992 (USA) | Prospective | Urology clinic | NR | NR | | NR | TT, PRL, LH | NR | ≥18 ng/ml | NR | NR
El-Sakka 2005 (Egypt) | Prospective | Andrology clinic | IIEF | Endocrinopathy (297) - 51.9 ± 12.2 No endocrinopathy (951) - 52.3 ± 11.7 | | Obesity, diabetes, hypertension, ischemic heart disease, dyslipidemia, cerebrovasular stroke | TT, PRL, LH, FSH | morning | >20 ng/ml | 4.1–20 ng/ml | ECLA
El-Sakka 2006 (Egypt) | Prospective | Andrology clinic | IIEF | 53.9 ± 8.5 | 26–86 | overweight, DM, hypertension, IHD, dyslipidemia, psych. Dis. | TT, PRL | NR | >20 ng/ml | 4.1–20 ng/mL | ECLA
Low 2006 (Malaysia) | Prospective | Community | IIEF-5 | 59.3 ± 7.38 | | depression | cFT, TT, PRL, LH | before 11 AM | >18.8 mcg/l | NR | direct CMI

5 Baseline serum levels: T = total testosterone; Pr = prolactin; LH = luteinizing hormone; FSH = follicle-stimulating hormone SD = standard deviation; n = number of events; N = total number of participants; % = prevalence; 2X: test was performed twice

Assay: chemiluminescent microparticle immunoassay (cmi); electrochemiluminescence immunoassay (ECLA), radioimunoassay (RIA), enzyme immunoassay (EIA)

Scales: Sex Health Inventory for Men (SHIM); sexual functioning questionnaire (SFQ);

* calculated free testosterone,

st if 1 test elevated, serial measurements in a rested state at 0, 30, 60, and 90 minutes

### Prevalence of Hyperprolactinemia (Serum Levels of Prolactin)

The information on prevalence of hyperprolactinemia using the total level of serum prolactin was reported in 10 studies (Table 6). Erectile dysfunction was diagnosed using a combination of clinical examination and a validated questionnaire (IIEF-5 was reported in only four of the 10 included studies). Information on the cut-off used to define a positive test result was provided in all studies and ranged from 18 to 20 ng/mL. In these studies, except for one conducted in Egypt, ^72^ the prevalence of hyperprolactinemia ranged from 1.42 to 14.3 percent.

Table 6 Prevalence of Hyperprolactinemia in Men with Erectile Dysfunction (serum prolactin levels)

Study Details^ 6 ^ | Study Design | Setting | T Mean(SD) | Prolactin Mean(SD) | LH Mean(SD) | FSH Mean(SD) | Hyperprolactinemia | | | Test time | Cut-off (PRL) | Normal Range | Assay
n | N | %
Studies performed in North America
Akpunonu 1994 (USA) | Prospective | Primary care clinics | 14±5.1 | 6.3 ± 6.5 mcg/L | 10.6±5.8 IU/L | 14.7±8.6 IU/L | 3 | 212 | 1.42 | - | >20 mcg/l | O-20 | NR
Johnson 1992 (USA) | Prospective | Urology clinic | NR | NR | NR | NR | 1 | 7 | 14.29 | - | ≥18 ng/ml | NR | NR
Studies performed in Europe
Buvat 1997 (France) | Prospective | Urology clinic | NR | NR | NR | NR | 3 | 451 | 0.67 | Morning | 20 ng/ml (high 20–35; highest >35) | NR | RIA
Hatzichristou 2002 (Greece) | Prospective | Andrology clinic | NR | NR | NR | NR | 8 | 1276 | 0.63 | - | NR | NR | NR
Acar 2004 (Turkey) | Prospective | NR | 4.9±1.7 | 10.6 ± 6.4 | 5±3.9 | 6.9±7.7 | 25 | 262 | 9.54 | Morning | >18ng/ml (2x) | NR | ECLA
Other countries
Earle 2003 (Australia) | Prospective | Department of endocrinology and diabetes | 7.8 (1–10) [101 men with low TT] | 48–7800 μg/L [7 men with hith PRL | 20 (10–56) U/L [18 men with high LH] | NR | 7 | 1455 | 0.48 | Morning^‡^ | NR | NR | RIA
Netto 1993 (Brazil) | Prospective | Primary care | NR | NR | NR | NR | 23 | 600 | 3.83 | Morning | 20 ng/ml | NR | RIA
Low 2006 (Malaysia) | Prospective | Community | 17.4±6.5 | 8.9±7.99 mcg/L | NR | NR | 7 | 242 | 2.89 | Before 11 AM | > 18.8 mcg/l | NR | direct CMI
El-Sakka 2005 (Egypt) | Prospective | Andrology clinic | 1.8±0.9 | 34 ± 13.9 ng/mL | NR | NR | 171 | 1248 | 13.7 | NR | >20 ng/ml | 4.1–20 | ECLA
El-Sakka 2006 (Egypt) | Prospective | Andrology clinic | Baseline - 5.1±1.3 Final visit - 3.5 ±1.3 | NS | NR | NR | 97 | 305 | 32 | NR | >20 ng/ml | 4.1–20 | ECLA

6 Baseline serum levels: T = total testosterone; LH = luteinizing hormone; FSH = follicle-stimulating hormone SD = standard deviation; n = number of events; N = total number of participants; % = prevalence

Assay: chemiluminescent microparticle immunoassay (CMI); electrochemiluminescence immunoassay (ECLA), radioimunoassay (RIA); automated enzyme immunoassay system (AEIA)

st 1 test elevated, serial measurements in a rested state at 0, 30, 60, and 90 minutes

The prevalence rate of hyperprolactinemia reported in the Egyptian study was 32 percent. ^72^ The high prevalence observed in this study is not readily explained. Study participants were aging, obese men with ED. Of a total of 877 enrolled patients, 305 completed the study. The mean age was 53.9 (range 26–86) years; 77 percent of the patients were older than 50 years, 86 percent were overweight or obese, and 30 percent were current or former smokers. ^72^

In two other studies, the prevalence rates of hyperprolactinemia were compared between men with and without ED. ^60,^ ^73^ These studies used similar cut-off points to define a positive or negative test result (Table 7). The prevalence rate of hyperprolactinemia among men with ED in the two studies ranged from 2.89 to 9.54 percent.

Table 7 Prevalence of Hyperprolactinemia in Men with and without Erectile Dysfunction (serum prolactin levels)

Study Details^ 7 ^ | Study Design | Setting | Hyperprolactinemia | | | Hyperprolactinemia | | | Test time | Cut-off (PRL) | Normal Range | Assay
n | N | % | n | N | %
Acar 2004 (Turkey) | Prospective | NR | 25 | 262 | 9.54 | 2 | 53 | 3.77 | Morning | >18ng/ml (2x) | NR | ECLA
Low 2006 (Malaysia) | Prospective | Primary care | 7 | 242 | 2.89 | 1 | 109 | 12.5 | before 11 AM | >18.8 mcg/l | NR | direct CMI

### Prevalence of Abnormal Levels of LH/FSH

Information on the prevalence of abnormal levels of LH/FSH in men with ED was provided for eight studies. ^20,^ ^61,^ ^63^ – ^65,^ ^67,^ ^69,^ ^73^ The studies were divided according to whether they measured secondary hypogonadism (low levels of LH and/or FSH) or primary hypogonadism (high levels of LH and/or FSH). All studies included men with a previous diagnosis of ED. In two studies levels of LH were measured only in patients with low levels of total testosterone. ^61,^ ^63^ The diagnosis of ED was done by a combination of clinical examination and validated questionnaire (IIEF-5 or SAQ; reported in three included studies). The cut-off values used to define a positive/negative test result were provided for two studies only (Tables 8 and 9).

Table 8 Population Characteristics of Studies Measuring Serum LH/FSH Levels in Men with Erectile Dysfunction

Study Details^ 8 ^ | Study Design | Setting | ED Scale | Age | | Comorbidity | Serum Levels | Test time | Cut-off (LH/FSH) | Normal Range (LH/FSH) | Assay
Mean(SD) | Range
Jaffe 1996 (Israel) | Prospective | clinic | - | 55.3 | | Hypertension | TT, BT, PRL, LH, FSH | Morning | LH: >15 mIU/mL; FSH: NR | NR | EIA
Earle 2003 (Australia) | Prospective | Department of Endocrinology and Diabetes | NR | 54.9 | 16–82 | Prostate cancer, secondary hypogonadism | TT, PRL, LH, FSH | NR | >10U/L | LH: 2–9 U/L | RIA
Bunch 2002 (USA) | Retrospective | outpatients | NR | 64.6 ± 10.8 | 51–85 | DM, IHD, hypertension, hyperlipidemia, depression, sleep apnea, CVA, AF, hypothyroidism, prostate cancer, CRF, head tumors, compression fractures | TT, LH | NR | LH: <13nIU/ml | NR | RIA
Fahmy 1999 (UK) | Prospective | ED clinic | sexual activity questionneire | NR | NR | NR | TT, FSH, PRL | morning (9–11 am) | NR | NR | NR
Akpunonu 1994 (USA) | Prospective | Primary care clinic | NR | 55.4±10 | 24–76 | Renal failure, DM | TT, PRL, LH, FSH | NR | NR | LH: 5–20 IU/L; FSH: 5–20 IU/L | NR
Johnson 1992 (USA) | Prospective | Urology clinic | NR | NR | | NR | TT, PRL, LH | NR | NR | NR | NR
El-Sakka 2005 (Egypt) | Prospective | Andrology clinic | IIEF | Endocrinopathy (297) -51.9 ± 12.2 No endocrinopathy (951) -52.3 ± 11.7 | | Obesity, diabetes, hypertension, ischemic heart disease, dyslipidemia, cerebrovasular stroke | TT, PRL, LH, FSH | NR | LH <1.3 mIU/mL; FSH <0.9 mIU/mL | NR | ECLA
Guay 1991 (USA) | Prospective | Endocrinology clinic | - | 53.2 ± 9.1 | | NR | TT, LH, FSH | Morning | NR | LH: 2–20 mIU/L; FSH: 2–10 mIU/L | RIA
Low 2006 (Malaysia | Prospective | Community | IIEF-5 | 59.3 ± 7.38 | | Depression | cFT, TT, PRL, LH | Morning (before 11am) | >12 IU/l | NR | direct CMI

8 Baseline serum levels: T = total testosterone; Pr = prolactin; LH = luteinizing hormone; FSH = follicle-stimulating hormone SD = standard deviation; n = number of events; N = total number of participants; % = prevalence

Assay: chemiluminescent microparticle immunoassay (CMI); electrochemiluminescence immunoassay (ECLA), radioimunoassay (RIA), enzyme immunoassay (EIA)

8 calculated free testosterone; the cut for LH > 15mIU/ml was used to define primary hypogonadism

Scales: Sex Health Inventory for Men (SHIM); sexual functioning questionnaire (SFQ);

Table 9 Prevalence of Primary or Secondary Hypogonadism in Men with Erectile Dysfunction (total serum levels of LH and FSH)

Study details^ 10 ^ | Study design | Setting | T Mean(SD) | PRL Mean(SD) | LH Mean(SD) | FSH Mean (SD) | LH/FSH | | | Test time | Cut-off (TT) | Normal range | Assay
n | N | %
Secondary hypogonadism (Low levels of LH and/or FSH)
Bunch 2002 (USA) | Retrospective* | Outpatients | 177.73 ± 78.36 ng/dL | NR | 6.8±9.1 mIU/ml | NR | ↓LH: 29^‡^ | 66 | 43.9 | NR | <13 mIU/ml | NR | RIA
El-Sakka 2005 (Egypt) | Prospective | Andrology clinic | 1.8±0.9 ng/mL | 34 ± 13.9 ng/mL | NR | NR | ↓LH/ FSH: 21 | 1248 | 1.68 | morning | NR | NR | ECLA
Primary hypogonadism (High levels of LH and/or FSH)
Akpunonu 1994 (USA) | Prospective | Primary care clinics | 14±5.1 nmol/L | 6.3 ± 6.5 mcg/L | 10.6±5.8 IU/L | 14.7±8.6 IU/L | ↑LH: 2 | 194 | 1.03 | NR | NR | 5–20 IU/L | -
↑FSH: 0 | 194 | 0
Johnson 1992 (USA) | Prospective | Urology clinic | NR | NR | NR | NR | ↑LH: 5 | 330 | 1.52 | NR | NR | NR | RIA
Earle 2003 (Australia) | Prospective | Department of Endocrinology and Diabetes | 7.8 (1–10) [101 men With ↓TT] | 48–7800 μg/L [7 men with ↑PRL] | 20 (10–56) U/L [18 men with ↑LH] | NR | ↑LH: 18 | 83 (all ↓TT) | 21.7 | morning | NR | 2–9 U/L | RIA
Fahmy 1999 (UK) | Prospective | ED clinic | NR | NR | NR | NR | ↓FSH: 1 | 90 | 1.11 | morning | NR | NR | NR
Guay 1991 (USA) | Prospective | Endocrinology | NR | NR | NR | NR | ↓LH:6 | 21 | 28.6 | NR | Gonadotropin reserve (≥20mIU/mL ↑ in LH, FSH) | NR | RIA
↓FSH: 1 | 21 | 4.76
Low 2006 (Malaysia) | Prospective | primary care | 17.4±6.5 | NR | NR | NR | ↓LH: 14 | 242 | 5.79 | NR | NR | NR | CMI

10 Baseline serum levels: T = total testosterone; Pr = prolactin; LH = luteinizing hormone; FSH = follicle-stimulating hormone SD = standard deviation; n = number of events; N = total number of participants; % = prevalence

Assay: chemiluminescent microparticle immunoassay (CMI); electrochemiluminescence immunoassay (ECLA), radioimunoassay (RIA)

* All patients in those studies were diagnosed with ED and hypogonadism at baseline;

‡ secondary hypogonadism caused by hypothalamic-pituitary structural abnormalities;

¥ approximately 2/3 of men on this study were using testosterone gel

Secondary hypogonadism (low levels of LH and/or FSH). In Bunch et al. 2002, 66 patients with hypogonadism were screened for LH levels. Of these, 44 percent had low levels of LH (<13 IU/mL) and were diagnosed with secondary hypogonadism. Further screening with magnetic resonance imaging (MRI) or computer tomography (CT) imaging led to the identification of hypothalamic-pituitary abnormalities in 10 percent of these men. ^63^

El-Sakka 2005 ^67^ assessed the prevalence of endocrine abnormalities in obese men with sexual dysfunction. Low levels of LH and FSH were identified only in 1.7 percent of men (Table 9).

Primary hypogonadism (high levels of LH and/or FSH). In three studies, the proportion of men with ED who had abnormally high levels of LH ranged from 1.03 to 5.79 percent. ^20,^ ^65,^ ^73^ There was a prevalence of 21.7 percent in a study in which all men had been previously diagnosed with hypogonadism (i.e., low testosterone levels). ^61^ Another study ^69^ investigated possible hypothalamic impotence in 21 ED patients (median age 54 years) with low testosterone and normal levels of LH or FSH by undergoing gonadotropin-releasing hormone (GnRH) stimulation and a challenge test with clomiphene citrate. Twenty-nine percent of men presented with a reduced LH level and 5 percent with a reduced FSH level. ^69^

### Prevalence of Hypogonadism and Hyperprolactinemia by Age

We descriptively examined patients' age distribution (mean and range) in individual studies to determine whether age could account for the between-study differences in the reported prevalence rates of hypogonadism and hyperprolactinemia. The results did not reveal any numerical trends between the age distribution and the prevalence rates.

Studies reporting age-stratified prevalence rates of hypogonadism. Buvat et al. 1997 ^38^ reported the prevalence of hypogonadism in patients older than 50 years as being twice as high as that among patients younger than 50 years (9 percent versus 4 percent). ^38^ In Fahmy et al. 1999 ^64^ the corresponding rates were 24.2 percent versus 14.3 percent, respectively. In another study, the prevalence rate in men older than 50 years was 20.25 percent (all patients were older than 50 years). ^73^ All three studies indicated higher prevalence of hypogonadism in men aged 50 years or older compared with those under 50 years of age.

Studies reporting age-stratified prevalence rates of hyperprolactinemia or abnormal levels of LH/ FSH. There was no report providing evidence on prevalence of hyperprolactinemia, or on abnormal levels of LH/FSH, by age group among patients with ED.

## The Efficacy of Hormonal Therapy in Treating Erectile Dysfunction in Patients with Hormonal Abnormalities

### Overview of Trials

Two studies were identified and were judged to be eligible to address the present question. Both trials were randomized ^5,^ ^77^ comparing the efficacy of combined treatment of testosterone (gel or patch) plus sildenafil to that of sildenafil alone in ED patients with low testosterone levels who failed to respond (score of 2–3 on IIEF-Q3/Q4) to prior treatment with sildenafil. More detailed information on trial design, patient population, and efficacy/harms results for these trials are presented in the section for Questions 2–3, Hormonal Treatments. (Evidence Table F-9, Appendix F)

Gel testosterone plus sildenafil versus sildenafil. In this double-blind trial ^5^ 75 hypogonadal men (mean age: 58 years; total testosterone <400 ng/dL) with ED were randomized to 1 percent gel testosterone plus 100 mg sildenafil versus 100 mg sildenafil for 12 weeks. At the end of the study, the proportions of men with scores of 4–5 on IIEF-Q3/Q4 was statistically nonsignificantly greater in the combination therapy group than in the sildenafil only group (51.4 versus 39.4 percent; RR = 1.30, 95 percent CI 0.77–2.21). Men who received gel testosterone plus sildenafil also had greater mean change from baseline in the IIEF “EF” domain score at week 4 (4.4 versus 2.1, 95 percent CI: 0.3–4.7). One patient withdrew from the combination treatment arm due to an adverse event.

Testosterone patch plus sildenafil versus sildenafil. In this open label trial,77 20 hypogonadal men (mean age:56 years; total testosterone:10–13 nmol/L) with ED were randomized to receive either 5 mg patch testosterone plus 100 mg sildenafil or 100 mg sildenafil plus placebo patch. After one month of treatment, patients in the patch testosterone plus sildenafil group had either numerically or statistically significant improvements for the following outcomes: “EF domain” score (21.8 +/- 2.1 versus 14.2 +/- 0.7, WMD = 7.60, 95 percent CI: 6.23–8.97), number of sexual intercourses (2.8 +/- 0.9 versus 1.5 +/- 0.5, WMD = 1.30, 95 percent CI: 0.66–1.94), intercourse satisfaction (12.1 +/- 1.6 versus 7.7 +/- 1.2, WMD = 4.40, 95 percent CI: 3.16–5.64), and reported improved erections (80 versus 10 percent, RR = 8.00, 95 percent CI: 1.21–52.69).

## Questions 2–3. What is the Evidence of the Relative Clinical Benefits and Harms of Pharmaceutical Treatments (e.g. Oral Medications) for Men Diagnosed With Erectile Dysfunction?

## Oral Treatments — Phosphodiesterase Type 5 (PDE-5) Inhibitors - Sildenafil

### Literature Search

In total, 90 unique trials (reported in 100 publications) reporting relative efficacy and harms related to sildenafil use (mono or combined therapy) met the eligibility criteria and were included in the review. ^5,^ ^77^ – ^175^

Seventeen (reported in 16 publications) of the 90 trials are described in the following sections of the review: Question 1–3, ^5,^ ^77^ Topical, ^144^ Hormonal, ^145,^ ^170^ Injections, ^119,^ ^172^ Tadalafil, ^103,^ ^118,^ ^121,^ ^163^ and Sublingual (apomorphine). ^114,^ ^117,^ ^120,^ ^148,^ ^159^

This section reviews the remaining 73 unique trials (reported in 84 publications). ^78^ – ^102,^ ^104^ – ^113,^ ^115,^ ^116,^ ^122^ – ^143,^ ^146,^ ^147,^ ^149^ – ^158,^ ^160^ – ^162,^ ^164^ – ^169,^ ^171,^ ^173^ – ^175^

In 5 publications, ^85,^ ^86,^ ^90,^ ^130,^ ^152^ two separate unique trials were described (a and b). 12 unique trials were reported in two or more publications. The following list shows the reference identifications for these 12 unique trials and their corresponding publications (each row).

The first reference (author, year, citation) denotes primary publications (i.e., those reporting the most relevant and complete data for the trial), which are used throughout the Sildenafil section. (Tables F-1, in Appendices F):

1 Palmer 2000 ^78^ and Palmer 1999 ^136^
2 Seidman 2001 ^79^ and Rosen 2004 ^113^
3 Goldstein 1998a, ^86^ Padma-Nathan 1999, ^154^ and Barry 1998a ^152^
4 Tan 2000 ^87^ and Lim 2002 ^129^
5 Meuleman 2001 ^88^ and Hartmann 1999 ^140^
6 Eardley 2002 ^130^ and Eardley 1999 ^139^
7 Incrocci 2001 ^131^ and Incrocci 2003 ^92^
8 Cappelleri 2000 ^135^ and Lewis 2001 ^100^
9 Padma-Nathan 1998, ^142^ Goldstein 1998b ^86^ and Young 1999, ^141^ and Barry b, ^152^ and Shabsigh 1999b ^153^
10 Glina 2001 ^151^ , and Glina 2002 ^127^
11 Perimenis 2007 ^155^ , Perimenis 2004 ^116^
12 Sharma 2006 ^165^ , and Salonia 2007 ^174^

### Overview of Trials

Of the 73 trials, 52 (71 percent) used a parallel-arm design, ^79^ – ^84,^ ^86^ – ^88,^ ^90,^ ^91,^ ^94^ – ^98,^ ^101,^ ^104,^ ^106,^ ^107,^ ^109^ – ^112,^ ^115,^ ^122^ – ^126,^ ^128,^ ^133,^ ^135,^ ^138,^ ^142,^ ^143,^ ^147,^ ^151,^ ^155^ – ^158,^ ^160,^ ^162,^ ^166,^ ^167,^ ^169,^ ^171,^ ^173,^ ^175,^ ^176^ while the remaining 21 used a crossover design. ^78,^ ^85,^ ^89,^ ^93,^ ^99,^ ^102,^ ^105,^ ^108,^ ^130^ – ^132,^ ^134,^ ^146,^ ^149,^ ^150,^ ^161,^ ^164,^ ^165,^ ^168^

The trials were conducted in North America, ^78,^ ^79,^ ^81,^ ^84,^ ^86,^ ^90,^ ^91,^ ^94,^ ^102,^ ^105,^ ^109,^ ^122,^ ^132,^ ^135,^ ^142,^ ^147,^ ^156,^ ^158,^ ^160,^ ^161,^ ^166,^ ^167,^ ^169,^ ^171,^ ^173,^ ^177^ Australia, ^147,^ ^166^ South America, ^81,^ ^83,^ ^106,^ ^123^ – ^126,^ ^143,^ ^151,^ ^166^ Africa, ^83,^ ^110^ Europe, ^81,^ ^85,^ ^88,^ ^89,^ ^93,^ ^95,^ ^96,^ ^98,^ ^99,^ ^104,^ ^107,^ ^108,^ ^112,^ ^115,^ ^128,^ ^130,^ ^131,^ ^133,^ ^134,^ ^137,^ ^138,^ ^146,^ ^147,^ ^150,^ ^155,^ ^157,^ ^167^ and Asia. ^80,^ ^81,^ ^81,^ ^82,^ ^87,^ ^97,^ ^101,^ ^111,^ ^149,^ ^162,^ ^164^ – ^166,^ ^168,^ ^175^

The trials were published between 1996 ^85^ and 2007. ^155^ – ^158,^ ^160,^ ^161,^ ^173,^ ^175^

Fifty-three trials were supported by Pfizer ^78^ – ^87,^ ^89^ – ^91,^ ^93^ – ^99,^ ^107^ – ^110,^ ^115,^ ^122,^ ^124^ – ^126,^ ^128,^ ^131,^ ^133,^ ^135,^ ^137,^ ^138,^ ^142,^ ^143,^ ^146,^ ^147,^ ^151,^ ^156,^ ^158,^ ^160,^ ^161,^ ^164,^ ^166,^ ^167,^ ^169,^ ^171,^ ^173,^ ^175^ . Two Italian trials were supported by Sigma Tau. ^104,^ ^112^ The source of support was not reported for 10 trials. ^88,^ ^106,^ ^111,^ ^123,^ ^130,^ ^134,^ ^149,^ ^150,^ ^155^ Three trials had no source of support, ^101,^ ^157,^ ^162^ and five other trials reported other funding sources. ^102,^ ^105,^ ^132,^ ^165,^ ^168^ (Evidence Table F-1, Appendix F)

### Populations

Study participants in the included trials were men diagnosed with ED. The total and mean numbers of patients randomized across the 73 trials were 11,064 and 152, respectively. The number of randomized patients across all trials ranged from 12 ^85,^ ^169^ to 568. ^147^

In these trials the study population inclusion criteria were: adult males aged ≥18 years diagnosed with ED for ≥3 months before study enrolment and in a heterosexual relationship with a sexual partner. The most common reported reasons for the trial exclusion were the presence or history of penile/testicular deformity, cardiovascular disease, stroke, myocardial infarction, use of nitrates, any major hepatic or renal disease, spinal cord injury, retinitis pigmentosa, diabetes, major psychiatric disorder, alcohol/drug abuse or hypotension.

In 31 (42 percent) of the 73 trials the selection of ED patients was restricted to patients with the following conditions: spina bifida, ^78^ depression, ^79,^ ^91,^ ^115,^ ^167^ diabetes, ^81,^ ^93,^ ^94,^ ^98,^ ^101,^ ^112^ stable coronary artery disease, ^84^ Parkinson's disease, ^99^ congestive/chronic heart failure, ^102,^ ^109^ prostatectomy, ^104^ multiple sclerosis, ^107^ dialysis, ^108,^ ^123^ obstructive sleep apnea, ^155^ colorectal cancer, ^128^ prostate cancer, ^131^ cardiovascular disease, ^133^ hypertension, ^143,^ ^147^ benign prostatic hyperplasia (BPH), ^160^ post-traumatic stress disorder, ^164^ renal allograft, ^165^ schizophrenia, ^168^ lower urinary tract symptoms, ^173^ and androgen decline. ^175^ Most patients (≥ 90 percent) included in the 31 trials were diagnosed with ED of organic and/or mixed etiology. ^78,^ ^79,^ ^81,^ ^84,^ ^91,^ ^93,^ ^94,^ ^98,^ ^99,^ ^101,^ ^102,^ ^104,^ ^107^ – ^109,^ ^112,^ ^115,^ ^123,^ ^128,^ ^131,^ ^133,^ ^143,^ ^147,^ ^155,^ ^160,^ ^164,^ ^165,^ ^167,^ ^168,^ ^173,^ ^175^ Of the remaining 42 trials, ^80,^ ^82,^ ^83,^ ^85^ – ^90,^ ^95^ – ^97,^ ^105,^ ^106,^ ^110,^ ^111,^ ^122,^ ^124^ – ^126,^ ^130,^ ^132,^ ^134,^ ^135,^ ^137,^ ^138,^ ^142,^ ^146,^ ^149^ – ^151,^ ^156^ – ^158,^ ^161,^ ^162,^ ^166,^ ^169,^ ^171^ three ^96,^ ^106,^ ^110^ included participants with ED of psychogenic etiology and another three consisted mostly of participants with ED of organic/vasculogenic and mixed etiology. ^122,^ ^150,^ ^157^ Participants included in the remaining 36 trials were diagnosed with ED with a broad spectrum of causes (i.e., organic, mixed, and psychogenic). The majority of these trials reported that an organic cause of ED had not been established.

The 73 trials included here enrolled participants aged 18 years or older. In one trial, ^78^ the participants' age ranged between 19 and 35 years, and in two trials this range was from 35 to 70 years. ^130^ Two trials included only participants older than 45 years. ^160,^ ^175^

### Interventions

In the 73 reviewed trials, participants were randomly assigned to receive either mono and/or combined therapy of oral sildenafil citrate (as experimental or control intervention) with a dose (at randomization) ranging from 10 mg ^85,^ ^96^ to 100 mg. ^101,^ ^104,^ ^122,^ ^130,^ ^134,^ ^137,^ ^146,^ ^150,^ ^155,^ ^158,^ ^161,^ ^169^ Depending on the observed efficacy and tolerability of sildenafil, the daily dose was flexible (upward or downward titrations: 50 mg - 25 mg - 100 mg) in more than half of the included trials. ^79^ – ^84,^ ^87^ – ^91,^ ^94,^ ^95,^ ^97^ – ^99,^ ^107^ – ^109,^ ^115,^ ^124^ – ^126,^ ^128,^ ^131,^ ^133,^ ^135,^ ^138,^ ^142,^ ^143,^ ^147,^ ^150,^ ^151,^ ^156,^ ^157,^ ^160,^ ^162,^ ^164^ – ^168,^ ^171^

In eight trials, participants were randomized to receive different dosages (e.g. with respect to dose, dose escalation, fixed/on demand, time of administration) of sildenafil monotherapy. ^78,^ ^85,^ ^86,^ ^93,^ ^96,^ ^137,^ ^157,^ ^161^ Of these, six trials ^78,^ ^85,^ ^86,^ ^93,^ ^96,^ ^137^ assessed a dose-response effect of sildenafil given at a fixed dose (dose range 10 mg/d to 100 mg/d). In one trial, ^161^ participants were randomly assigned to receive 100 mg/d of sildenafil either 1 hour before/during a meal or 30–60 minutes before sexual activity. Participants in another trial were randomly assigned to receive either fixed dosing (50 mg every night) or flexible dosing (50 mg or 100 mg, as needed) of sildenafil. ^157^

In nine trials, oral sildenafil was administered in combination with propionyl-L-carnitine (PLC), ^112^ PLC and acetyl-L-carnitine (ALC), ^104^ intranasal PT-141, ^105^ psychotherapy, ^106^ alfuzosin, ^173^ dihydro-ergotamine (DHE), ^150^ atorvastatin, ^158,^ ^169^ quinapril, ^158^ and cabergoline. ^162^

In five trials, patients received either mono (or combined) therapy of sildenafil or monotherapy of another active treatment. ^106,^ ^124,^ ^132,^ ^155,^ ^173^ These therapies were psychotherapy, ^106^ continuous positive air pressure (CPAP), ^155^ phentolamine, ^124^ Ro70-0004 (i.e., α_1A_-adrenoceptor antagonist), ^132^ or alfuzosin. ^173^

Of the 73 trials, 66 (91 percent) were placebo-controlled (with or without an active treatment arm), ^78^ – ^91,^ ^93^ – ^99,^ ^101,^ ^102,^ ^104,^ ^105,^ ^107^ – ^111,^ ^115,^ ^122,^ ^123,^ ^125,^ ^126,^ ^128,^ ^130^ – ^135,^ ^137,^ ^138,^ ^142,^ ^143,^ ^146,^ ^147,^ ^149,^ ^151,^ ^156,^ ^158,^ ^160^ – ^162,^ ^164^ – ^169,^ ^171,^ ^175^ and the remaining seven trials had no placebo arm. ^106,^ ^112,^ ^124,^ ^150,^ ^155,^ ^157,^ ^173^

In most of the trials, the duration of sildenafil treatment was about 12 weeks ^79^ – ^81,^ ^83,^ ^84,^ ^87,^ ^94,^ ^97,^ ^98,^ ^102,^ ^107,^ ^109,^ ^115,^ ^125,^ ^126,^ ^131,^ ^133,^ ^135,^ ^137,^ ^138,^ ^142,^ ^151,^ ^155,^ ^156,^ ^158,^ ^160,^ ^166,^ ^169,^ ^171,^ ^173,^ ^175^ and ranged from 1–2 weeks ^93,^ ^168^ to 48 weeks. ^157^

### Outcomes

Harms. The presence or absence of any all-cause adverse events (i.e., the proportion of patients with ≥ 1 adverse event) was reported in 29 trials. ^79^ – ^83,^ ^85^ – ^87,^ ^90,^ ^94,^ ^96^ – ^98,^ ^107^ – ^109,^ ^115,^ ^124^ – ^126,^ ^132,^ ^137,^ ^142,^ ^143,^ ^147,^ ^151,^ ^160^ The presence or absence of withdrawals due to adverse events was reported in 62 trials. ^78^ – ^91,^ ^94^ – ^99,^ ^101,^ ^104,^ ^105,^ ^107^ – ^109,^ ^112,^ ^115,^ ^122^ – ^126,^ ^128,^ ^130,^ ^131,^ ^133^ – ^135,^ ^137,^ ^138,^ ^142,^ ^143,^ ^146,^ ^147,^ ^149,^ ^151,^ ^155^ – ^157,^ ^160,^ ^162,^ ^165^ – ^168,^ ^171,^ ^173,^ ^175^ The absence or presence of serious adverse events was reported in 52 trials. ^78,^ ^80^ – ^85,^ ^87^ – ^91,^ ^93,^ ^95^ – ^99,^ ^101,^ ^105,^ ^107^ – ^112,^ ^123^ – ^126,^ ^128,^ ^131,^ ^133^ – ^135,^ ^138,^ ^143,^ ^146,^ ^147,^ ^149,^ ^151,^ ^155^ – ^157,^ ^160,^ ^166^ – ^168,^ ^171,^ ^173^

Efficacy. The efficacy outcomes measuring the degree of ED reported in the 73 trials were total mean scores for the 5 IIEF domains: “Erectile Function”, ^79^ – ^84,^ ^86^ – ^88,^ ^90,^ ^91,^ ^97,^ ^98,^ ^102,^ ^104,^ ^107^ – ^109,^ ^112,^ ^115,^ ^122^ – ^126,^ ^128,^ ^135,^ ^137,^ ^138,^ ^142,^ ^143,^ ^147,^ ^149,^ ^155,^ ^156,^ ^160,^ ^161,^ ^164^ – ^167,^ ^169,^ ^171,^ ^173^ “Intercourse Satisfaction”, ^79,^ ^80,^ ^82^ – ^84,^ ^87,^ ^88,^ ^90,^ ^91,^ ^97,^ ^104,^ ^107^ – ^109,^ ^115,^ ^122^ – ^126,^ ^137,^ ^138,^ ^142,^ ^143,^ ^147,^ ^149,^ ^155,^ ^156,^ ^160,^ ^162,^ ^164^ – ^167,^ ^171^ “Overall Satisfaction”, ^79,^ ^80,^ ^82^ – ^84,^ ^87,^ ^88,^ ^90,^ ^91,^ ^97,^ ^104,^ ^107^ – ^109,^ ^115,^ ^122^ – ^126,^ ^137,^ ^138,^ ^142,^ ^143,^ ^147,^ ^149,^ ^155,^ ^156,^ ^160,^ ^164^ – ^167,^ ^171^ “Orgasmic Function”, ^79,^ ^80,^ ^82^ – ^84,^ ^87,^ ^88,^ ^90,^ ^91,^ ^97,^ ^104,^ ^107^ – ^109,^ ^115,^ ^122^ – ^126,^ ^137,^ ^138,^ ^142,^ ^143,^ ^147,^ ^149,^ ^155,^ ^156,^ ^160,^ ^164^ – ^167,^ ^171^ and “Sexual Desire”, ^79,^ ^80,^ ^82^ – ^84,^ ^87,^ ^88,^ ^90,^ ^91,^ ^97,^ ^104,^ ^107^ – ^109,^ ^115,^ ^122^ – ^126,^ ^137,^ ^138,^ ^142,^ ^147,^ ^149,^ ^155,^ ^156,^ ^160,^ ^164^ – ^167,^ ^171^

Other commonly reported outcomes were: mean IIEF scores for responses to Q3 and Q4 (penetration and maintenance frequency), ^79^ – ^84,^ ^86^ – ^88,^ ^90,^ ^91,^ ^94,^ ^97^ – ^99,^ ^101,^ ^107^ – ^109,^ ^112,^ ^115,^ ^123^ – ^126,^ ^131,^ ^133,^ ^137,^ ^138,^ ^142,^ ^143,^ ^147,^ ^149^ – ^151,^ ^162,^ ^165,^ ^167,^ ^173^ proportion of successful intercourse attempts, ^80^ – ^84,^ ^87,^ ^94,^ ^97,^ ^98,^ ^109,^ ^112,^ ^115,^ ^124^ – ^126,^ ^131,^ ^137,^ ^138,^ ^142,^ ^143,^ ^147,^ ^151,^ ^155,^ ^156,^ ^161,^ ^166,^ ^167,^ ^171^ and proportion of patients with improved erection (GEQ-Q1). ^79^ – ^90,^ ^93^ – ^98,^ ^107^ – ^109,^ ^112,^ ^115,^ ^124^ – ^126,^ ^128,^ ^131,^ ^133,^ ^137,^ ^138,^ ^142,^ ^143,^ ^147,^ ^149,^ ^151,^ ^156,^ ^165,^ ^167^ – ^169,^ ^171^

Several trials reported mean IIEF scores for individual questions (e.g. Q1–Q2 and Q5–Q15) ^78,^ ^94,^ ^101,^ ^123,^ ^124,^ ^126,^ ^131,^ ^138,^ ^143,^ ^150,^ ^162,^ ^165^ as well as the mean total IIEF score. ^91,^ ^106,^ ^123,^ ^128,^ ^155,^ ^164,^ ^175^

Other reported outcomes were mean severity score of ED (based on the modified 5-item IIEF), ^111,^ ^123,^ ^135,^ ^158^ time to onset of erections/intercourse attempts (i.e., mean/median number of minutes), ^122,^ ^130,^ ^161^ proportion of responders (erection rigidity >60 percent or erection grades 3–4), ^130,^ ^146^ duration of erections (≥60 percent or ≥80 percent rigidity), ^93,^ ^105,^ ^132,^ ^146,^ ^168^ mean number (per week or month) of penile erections (grade 3–4), ^85,^ ^88,^ ^89,^ ^93,^ ^95,^ ^96,^ ^138,^ ^142,^ ^168^ peak systolic/end diastolic velocity (PSV/EDV) in cm/s, ^104,^ ^108,^ ^112,^ ^157^ mean EDITS score, ^84,^ ^90,^ ^109,^ ^143,^ ^147,^ ^156,^ ^160,^ ^161,^ ^167^ mean score of responses to Self-Esteem and Relationship questionnaire (SEAR), ^156,^ ^160,^ ^166,^ ^171^ nocturnal penile tip and base tumescence/rigidity (in mean activity units), ^110,^ ^134^ and endothelial function (brachial artery flow-mediated dilation). ^158^

### Study and Reporting Quality

The mean of Jadad total score for the 73 trials was 3.3. The Jadad total score for the individual trials ranged from 1 ^99,^ ^124,^ ^132,^ ^150,^ ^178,^ ^179^ to 5. ^81,^ ^91,^ ^94,^ ^95,^ ^115,^ ^123,^ ^128,^ ^143,^ ^162,^ ^168^ The method for generating the sequence of randomization was described in only 26 trials, ^81,^ ^84,^ ^89,^ ^91,^ ^94,^ ^95,^ ^99,^ ^101,^ ^104,^ ^106,^ ^107,^ ^109,^ ^112,^ ^115,^ ^123,^ ^128,^ ^143,^ ^155^ – ^157,^ ^162,^ ^164,^ ^165,^ ^167,^ ^168,^ ^171^ and in four of these ^89,^ ^99,^ ^104,^ ^112^ the method was determined to be inappropriate.(Table C-1, Appendix C)

Of the 73 trials, 64 (88 percent) were described as double- blind ^79^ – ^91,^ ^93^ – ^99,^ ^101,^ ^102,^ ^104,^ ^105,^ ^107^ – ^109,^ ^111,^ ^112,^ ^115,^ ^122,^ ^123,^ ^125,^ ^126,^ ^128,^ ^130,^ ^131,^ ^133^ – ^135,^ ^137,^ ^138,^ ^142,^ ^143,^ ^146,^ ^147,^ ^149,^ ^151,^ ^156,^ ^158,^ ^160^ – ^162,^ ^164^ – ^169,^ ^171,^ ^175^ and nine trials as open-label. ^78,^ ^106,^ ^110,^ ^124,^ ^132,^ ^150,^ ^155,^ ^157,^ ^180^ Of the 64 double-blind trials, 42 (66 percent) reported some description of the blinding methods. ^79^ – ^83,^ ^86^ – ^91,^ ^94,^ ^95,^ ^97,^ ^98,^ ^102,^ ^104,^ ^107,^ ^108,^ ^112,^ ^115,^ ^122,^ ^123,^ ^125,^ ^128,^ ^30,^ ^133,^ ^134,^ ^137,^ ^138,^ ^142,^ ^143,^ ^151,^ ^158,^ ^162,^ ^164,^ ^168,^ ^169,^ ^173,^ ^175^ The blinding methods reported for two trials ^102,^ ^146^ were judged to be inappropriate.

Information on methods for allocation concealment was reported for only 11 trials. ^81,^ ^91,^ ^94,^ ^95,^ ^101,^ ^106,^ ^107,^ ^112,^ ^123,^ ^156,^ ^165^ The methods reported for 10 trials were judged to be adequate, ^81,^ ^91,^ ^94,^ ^95,^ ^101,^ ^106,^ ^107,^ ^112,^ ^123,^ ^165^ and for one trial inadequate. ^156^ The methods used to conceal the treatment allocation for the remaining 61 trials could not be ascertained (i.e., these were rated “unclear”).

Of the 21 crossover studies, seven (33 percent) reported the use of washout periods, ^85,^ ^130,^ ^132,^ ^146,^ ^150,^ ^165^ and one study reported not to have employed a washout period. ^89^ For the remaining 13 trials, it was not clear whether any washout periods were applied. ^78,^ ^93,^ ^99,^ ^102,^ ^105,^ ^108,^ ^130,^ ^131,^ ^134,^ ^149,^ ^161,^ ^164,^ ^168^ The length of washout period for the seven crossover trials was 4 days, ^150^ 7 days, ^85,^ ^130,^ ^132,^ ^146^ and 2 weeks. ^165^

### Qualitative Synthesis

Sildenafil (mono or combination therapy) versus placebo. In four placebo-controlled trials ^158,^ ^161,^ ^162,^ ^169^ the efficacy and safety profiles of sildenafil and placebo were not compared (see sildenafil dose/dosage one versus dose/dosage two and sildenafil mono versus sildenafil in combination sections). Thus, results provided here are based on data obtained from 62 placebo-controlled trials. ^78^ – ^91,^ ^93^ – ^99,^ ^101,^ ^102,^ ^104,^ ^105,^ ^107^ – ^111,^ ^115,^ ^122,^ ^123,^ ^125,^ ^126,^ ^128,^ ^130^ – ^135,^ ^137,^ ^138,^ ^142,^ ^143,^ ^146,^ ^147,^ ^149,^ ^151,^ ^156,^ ^160,^ ^164^ – ^168,^ ^171,^ ^175^

Harms. In the majority of the placebo-controlled trials, the proportion of patients with at least one adverse event was greater either numerically or with statistical significance for participants taking sildenafil compared with those taking placebo. For example, in one trial of flexible dose (titrated to 100 or 25 mg), 51.3 percent and 32.9 percent of patients experienced one or more adverse events in sildenafil and placebo arms, respectively (p values were not reported). ^125^ In another study, the corresponding proportions were 59.7 percent for the sildenafil treatment group versus 29.6 percent for the placebo arm, respectively (p = 0.079). ^126^

The most commonly observed all-cause adverse events across the trials were headache, flushing, and dyspepsia. Other adverse events were myalgia, rhinitis, cardiovascular events, flu- like symptoms, nausea, respiratory events, diarrhea, vomiting, dizziness, chest pain, urinary tract infections, depression, and anxiety. Overall, these events were less frequent for participants taking placebo compared with those taking sildenafil. These effects were usually of a mild to moderate or transient nature not requiring discontinuation of the therapy.

The occurrence of specific adverse events involving visual disturbances, including blurry vision and chromatopsia, were reported in 33 trials. ^79^ – ^84,^ ^86,^ ^88,^ ^90,^ ^91,^ ^94,^ ^95,^ ^97,^ ^98,^ ^107,^ ^109,^ ^115,^ ^122,^ ^125,^ ^126,^ ^131,^ ^135,^ ^137,^ ^138,^ ^142,^ ^146,^ ^147,^ ^151,^ ^156,^ ^164,^ ^165,^ ^167^ The percentage of patients experiencing visual side effects across the trials ranged from 1 percent ^88,^ ^137,^ ^165^ to 57 percent ^164^ for participants taking sildenafil, and from 0 percent ^80,^ ^87,^ ^88,^ ^94,^ ^95,^ ^98,^ ^101,^ ^107,^ ^109,^ ^122,^ ^125,^ ^126,^ ^135,^ ^138,^ ^147,^ ^165,^ ^167,^ ^171^ to 61.9 percent ^164^ for participants taking placebo.

Cardiovascular events were reported in 18 studies. ^79,^ ^83,^ ^84,^ ^87^ – ^89,^ ^94,^ ^96,^ ^97,^ ^101,^ ^102,^ ^107,^ ^109,^ ^125,^ ^126,^ ^137,^ ^143,^ ^166^ These events were numerically more frequent in participants treated with sildenafil, ranging from 3 percent ^94^ to 29 percent, ^97^ compared with the range of 0 percent ^101^ to 12 percent ^97^ for placebo-treated participants.

A few studies reported the need for dose reduction as a result of adverse events. ^80,^ ^84,^ ^87,^ ^115,^ ^151^ The reasons for dose reduction were headache, ^80,^ ^87,^ ^151^ flushing, ^87^ chest tightness, ^87^ nasal stuffiness, ^87^ and visual disturbance. ^80^

Twenty-four trials reported the absence of withdrawals due to adverse events. ^78^ – ^80,^ ^82,^ ^85,^ ^98,^ ^104,^ ^105,^ ^107,^ ^110,^ ^112,^ ^128,^ ^131,^ ^133,^ ^134,^ ^138,^ ^146,^ ^149,^ ^156,^ ^167,^ ^168,^ ^171^ The rate of WDE (presented as the proportion of patients who withdrew) in sildenafil treatment groups was under 5 percent in 18 trials, ^81,^ ^83,^ ^84,^ ^88,^ ^90,^ ^91,^ ^96,^ ^109,^ ^115,^ ^125,^ ^135,^ ^137,^ ^142,^ ^151,^ ^156,^ ^160,^ ^175^ and up to 8 to 12.5 percent in four trials. ^96,^ ^99,^ ^101,^ ^126^ In the majority of these trials, the rate for withdrawals due to adverse events in placebo-treated participants ranged between 2 and 8.5 percent. The specific events leading to withdrawals were headache, ^88,^ ^101,^ ^109,^ ^137,^ ^142,^ ^151^ nausea, vomiting, gastrointestinal symptoms, ^86,^ ^88,^ ^137^ visual disturbances, ^88,^ ^165^ cardiovascular events, ^87,^ ^89,^ ^99,^ ^101,^ ^165,^ ^166^ urinary tract infection, ^166^ chest pain, ^101^ and cerebrovascular events. ^160^ These events were reported for participants treated with sildenafil, with the exception of one case of myocardial infarction ^89^ and one case of urinary tract infection ^166^ in placebo-treated participants.

The occurrence/absence of serious adverse events was reported in 51 trials. In 29 trials, no patient experienced any serious adverse event. ^78,^ ^80,^ ^81,^ ^85,^ ^90,^ ^91,^ ^98,^ ^99,^ ^101,^ ^105,^ ^108,^ ^110^ – ^112,^ ^124,^ ^125,^ ^128,^ ^131,^ ^133,^ ^134,^ ^138,^ ^146,^ ^149,^ ^156,^ ^157,^ ^167,^ ^168,^ ^173^ Thus, the occurrence of serious adverse events was reported in 22 trials (Table 10). ^82^ – ^84,^ ^87^ – ^90,^ ^93,^ ^95^ – ^97,^ ^107,^ ^109,^ ^123,^ ^126,^ ^135,^ ^143,^ ^147,^ ^151,^ ^160,^ ^166,^ ^171^ In general, the quality of reporting serious adverse events was poor, and some studies did not provide a full description of events. ^82,^ ^95,^ ^107,^ ^109,^ ^126,^ ^135,^ ^147,^ ^151,^ ^160,^ ^166^ In total, 95 participants had at least one serious adverse event while taking sildenafil or placebo, of which 32 were taking sildenafil ^83,^ ^84,^ ^87,^ ^88,^ ^90,^ ^93,^ ^97,^ ^107,^ ^109,^ ^126,^ ^135,^ ^143,^ ^147,^ ^151,^ ^160,^ ^166^ and 36 were taking placebo. ^82,^ ^84,^ ^87,^ ^89,^ ^97,^ ^107,^ ^109,^ ^123,^ ^126,^ ^135,^ ^143,^ ^147,^ ^151,^ ^160,^ ^166,^ ^171^ For the remaining 27 participants in two trials, ^95,^ ^96^ the treatment group designation was not reported. Cardiovascular events were the most frequent category of serious adverse events. These included myocardial infarctions, which occurred in one participant taking sildenafil, ^83^ two participants taking placebo, ^89,^ ^126^ and one participant whose group designation was unknown. ^96^ Severe angina pectoris occurred in a participant taking 100 mg sildenafil ^87^ and in another patient taking placebo. ^84^ Heart failure, atrial fibrillation, and arrhythmia occurred in two participants taking sildenafil. ^143^ Cerebrovascular events occurred in two participants taking sildenafil, ^143,^ ^160^ one of which was taking 100 mg of sildenafil. ^160^ Respiratory events included pneumococcal pneumonia in one participant on placebo ^143^ and pulmonary edema in another participant on sildenafil. ^143^ Accidental injuries were reported in two participants, one severe vertebral fracture in a participant taking sildenafil, ^83^ and the other a hand injury in a participant taking placebo. ^87^

Table 10 Serious Adverse Events in Sidenafil vs. Placebo (data from RCTs)

Author year | ED Population Country/Ethnicity | Serious Adverse Events n/N (%) | | Active dose | Description of Adverse Events (study arm)
Sildenafil | Placebo
Choi (2003) | All causes Asia-NR | 0/66 | 2/67 (3%) | Flexible 25–100 mg | - NR (CG)
Levinson (2003) | All etiologies Men from Egypt and South African | 3/128 (2.0%) | 0/126 | Flexible 25–100 mg | - Myocardial infarction (IG); - Accidental vertebral fracture (IG); - Diverticulitis (IG)
DeBusk (2004) | Stable coronary artery disease UK-NR | 1/75 (1.4%) | 2/76 (2.6%) | Flexible 25–100 mg | - Atypical chest pain (IG); - Acute UTI (CG); - Severe angina pectoris (CG)
Tan (2000) | All etiologies Men from Malaysia, Singapore and Philippines | 1/127 (<1%) | 1/127 (<1%) | Flexible 25–100 mg; IG pts on 100 mg | - Severe angina pectoris 4 hr post 100 mg sildenafil (pts with CAD); - Accidental hand injury (CG)
Meuluman (2001) | All causes Europe and US-NR | 2/159 (1.3%) | 0/156 | Flexible 25–100 mg | - Death due to accident (IG); - Death due to cardiac arrest (IG)
Young (2002) | All causes North America, Hispanic | 1/98 | 0/99 | Flexible 25–100 mg | - NR (IG)
Eardley (2001) | All causes UK-NR | 0/44 | 1/44 (2.3%) | Flexible dose 25–75 mg | - Myocardial infarction in a pt during 2^nd^ 28 d phase (CG)
Price (1998) | Diabetes type I and II UK-NR | 1/21 (4.7%) | 0/21 | 25 mg | - Pneumococcal pneumonia (IG)
Christiansen (2000) | All etiologies Europe-NR | 24/205 (11.7%), Group designation not reported | | 10 or 25 mg | - Death (open label phase, 10 mg); - Other events not described
Olsson (2000) | All etiologies Europe-NR | 3/351 (<1%); Group designation not reported | | Fixed 25, 50, 100 mg | - Myocardial infarction (NR); - Renal cell carcinoma (NR); - Epileptic crisis (NR)
Chen (2001) | All etiologies Taiwan-Asian | 4/119 (3.0%) | 4/117 (3.0%) | Flexible 25–100 mg | - No data provided
Fowler (2004) | Multiple sclerosis UK-NR | 3/104 (2.7%) | 3/113 (2.9%) | Flexible 25–100 mg | - NR (NR); - 12 (6%) of pts experienced SAE (relapse) during open label
Katz (2005) | Stable coronary heart failure Multi-Nation | 2/63 (3.0%) | 4/74 (5.0%) | Flexible 25–100 mg | - NR
Seibel (2002) | Renal failures Brazil-NR | 0/24 | 2/24 (8.0%) | Fixed 50 mg | - Deaths (CG)
Becher (2002) | All etiologies South America, Chile-Hispanic | 2/72 (2.8%) | 1/71 (1.4%) | Flexible 25–100 mg | - Death due to myocardial infarction (CG); - Remaining SAEs not described
Cappelleri (2000) | All etiologies US-NR | 3/124 (2.0%) | 3/123 (2.0%) | Flexible 25–100 mg | - NR
Albuquerque (2005) | Hypertensive men Brazil | 3/61 (5.0%) | 1/59 (1.7%) | Flexible 25–100 mg | - Cerebrovascular accident (IG); - Pulmonary edema/heart failure (IG); - Atrial fibrillation/arrhythmia (IG); - polytrauma (CG)
Pickering (2004) | Men with history of atrial hypertension Italy-NR | 2/281 (<1%) | 2/287 (<1%) | Flexible 25–100 mg | - NR
Glina (2001) | All etiologies Mexico-Brazilian/Mexican | 1/124 (<1%) | 5/121 (4%) | Flexible 25–100 mg | - NR
McVary (2007) | Men with lower urinary tract syndromes associated with prostatic hyperplasia US: 82% White | 2/189 (1.0%) | 3/181 (2.0%) | Flexible 25–100 mg | - Worsening of knee arthralgia (100 mg/ IG); - Severe acute cerebrovascular stroke (100 mg/ IG); - Remaining 3 cases were not described
Althof (2006) | All causes Multi-nation: White 55.5%; Black 15%; Asian 5.5%; Other 23.5% | 1/274 (<1%) | 1/279 (<1%) | NR | - Severe coronary artery disease (IG); - Urinary tract infection (CG)
O'Leary (2006) | All causes (also with low self-esteem) US: 62% White; 25% Black | 0/129 | 1/127 (<1%) | Flexible 25–100 mg | - Death (CG)

NR=not reported; CG=control group; IG=intervention group; pt(s)=patient(s)

Six deaths during four trials, ^88,^ ^123,^ ^126,^ ^171^ and one death during the open-label phase of the study ^95^ were reported. Four of the eight deaths occurred in placebo groups, one resulting from myocardial infarction. ^126^ The reasons for the other three deaths were not reported. ^123,^ ^171^ Two deaths occurred in participants treated with sildenafil; one of these resulted from an accident, ^123^ and the other from cardiac arrest. ^88^ For more details on serious adverse events in each trial, please refer to Table 10.

Efficacy. In the trials reporting mean scores for IIEF “EF” domain and IIEF-Q3/Q4, the proportions of patients with successful intercourse attempts, and improved erection demonstrated that participants receiving sildenafil (regardless of mono/combination therapy or dosage and duration) experienced a statistically significant greater improvement in erectile function compared with those receiving placebo. These improvements were observed for the mean total “EF domain” scores (38 trials), ^79^ – ^84,^ ^86^ – ^88,^ ^90,^ ^91,^ ^97,^ ^98,^ ^102,^ ^104,^ ^107^ – ^109,^ ^115,^ ^122,^ ^123,^ ^125,^ ^126,^ ^128,^ ^135,^ ^137,^ ^142,^ ^143,^ ^147,^ ^149,^ ^156,^ ^160,^ ^164^ – ^167,^ ^171^ mean IIEF Q3–Q4 scores (35 trials), ^79^ – ^84,^ ^86^ – ^88,^ ^90,^ ^91,^ ^94,^ ^97^ – ^99,^ ^101,^ ^107^ – ^109,^ ^115,^ ^123,^ ^125,^ ^126,^ ^131,^ ^133,^ ^137,^ ^138,^ ^142,^ ^143,^ ^147,^ ^149,^ ^151,^ ^165,^ ^167^ the proportion of successful intercourse attempts (25 trials), ^80^ – ^84,^ ^87,^ ^94,^ ^97,^ ^98,^ ^101,^ ^109,^ ^115,^ ^125,^ ^126,^ ^131,^ ^137,^ ^138,^ ^142,^ ^143,^ ^147,^ ^151,^ ^156,^ ^166,^ ^167,^ ^171^ and the proportion of patients with improved erection (based on their responses to GEQ-Q1) (all 40 trials). ^79^ – ^90,^ ^93^ – ^98,^ ^107^ – ^109,^ ^115,^ ^125,^ ^126,^ ^128,^ ^131,^ ^133,^ ^137,^ ^138,^ ^142,^ ^143,^ ^147,^ ^149,^ ^151,^ ^156,^ ^165,^ ^167,^ ^168,^ ^171^

All trials (i.e., those that reported mean scores for the five IIEF domains) except for one, ^164^ yielded statistically significant higher mean IIEF scores in participants treated with sildenafil compared with placebo-treated participants for two IIEF domains (“Intercourse Satisfaction” and “Overall Satisfaction”). ^79,^ ^80,^ ^82^ – ^84,^ ^87,^ ^88,^ ^90,^ ^91,^ ^97,^ ^104,^ ^107^ – ^109,^ ^115,^ ^122,^ ^123,^ ^125,^ ^126,^ ^137,^ ^138,^ ^142,^ ^143,^ ^147,^ ^149,^ ^156,^ ^160,^ ^165^ – ^167,^ ^171^ In general, the results for two IIEF domains of “Sexual Desire” and “Orgasmic Function” were less consistent that those for three other domains (i.e., “Erectile Function,” “Intercourse Satisfaction,” and “Overall Satisfaction”).

Specifically, in 17 trials no statistically significant difference was shown in mean IIEF scores for “Sexual Desire” between sildenafil and placebo groups. ^84,^ ^88,^ ^90,^ ^91,^ ^104,^ ^108,^ ^115,^ ^123,^ ^125,^ ^138,^ ^142,^ ^143,^ ^149,^ ^156,^ ^164,^ ^165^ In six trials, ^109,^ ^115,^ ^125,^ ^143,^ ^156,^ ^164^ the between-group (sildenafil versus placebo) differences for mean scores of “Orgasmic Function” were not statistically significant.

All seven trials ^85,^ ^88,^ ^89,^ ^93,^ ^95,^ ^96,^ ^168^ that assessed and reported the mean number of grade 3–4 erections per week, yielded a statistically significant increase in the mean number of erections among participants treated with sildenafil (range 1.3 ^93^ –6.5 ^168^ ) compared with placebo-treated participants (range 0.6 ^88,^ ^93,^ ^95^ –3.32 ^168^ ). Similarly, two other trials ^86,^ ^138^ showed that participants treaded with sildenafil compared with those on placebo, experienced a significantly greater mean number of erections (grade 3–4) per month. The ranges for the mean numbers of erections were 4.3–6.9 (sildenafil) and 2.4–3.1 (placebo). Five trials ^93,^ ^105,^ ^132,^ ^146,^ ^168^ indicated a statistically significant longer mean duration of erections (≥60 percent rigidity) for participants treated with sildenafil compared with those who received placebo.

In nine trials, mean EDITS scores indicated that participants exhibited a statistically significant higher degree of treatment satisfaction after being treated with sildenafil compared with placebo. ^84,^ ^90,^ ^109,^ ^143,^ ^147,^ ^156,^ ^160,^ ^167^

The beneficial effect of sildenafil use found in trials of participants with psychogenic ED ^96,^ ^110^ or distinct clinical subgroups (e.g. spina bifida, depression, diabetes, stable coronary artery disease, Parkinson's disease, congestive heart failure, multiple sclerosis, prostate cancer) ^78,^ ^79,^ ^81,^ ^84,^ ^91,^ ^93,^ ^94,^ ^98,^ ^99,^ ^101,^ ^102,^ ^104,^ ^107^ – ^109,^ ^115,^ ^123,^ ^128,^ ^131,^ ^133,^ ^143,^ ^147,^ ^160,^ ^164,^ ^165,^ ^167,^ ^168,^ ^175^ were consistent with those of other trials conducted in patients with ED of mixed etiology or those with clinically heterogeneous conditions.

Reports of only four trials provided treatment efficacy subgroup analyses (i.e., stratification of efficacy results) with respect to baseline severity of ED. ^81,^ ^90,^ ^128^ The evidence from these trials indicated that participants with mild/moderate ED (IIEF score 11–25) after taking sildenafil tended (statistically nonsignificant trends) to experience a greater degree of improvement in erectile function as measured by mean scores for responses to “EF domain” and Q3–Q4 of the IIEF questionnaire and the proportion of patients with improved erections (i.e., those who responded “yes” to GEQ-Q1) compared with those with severe ED (IIEF ≤10).

Efficacy subgroup analyses with respect to duration of ED (0–3, 3–6, and >6 years) and age (18–49, 50–64, and ≥65 years) were reported in two trials. ^94,^ ^101^ In both trials sildenafil was shown to have improved erectile function (i.e., mean IIEF-Q3/Q4 scores and percentage of patients who responded “yes” to GEQ-Q1) regardless of the participants' age and the duration of ED. The results of analyses provided for these trials did not reveal any treatment effect modification by the above-mentioned factors. In another trial, younger age (p = 0.034) and a shorter duration of ED (p = 0.028) were found to be predictive of a greater baseline-to-endpoint improvement in erectile function (i.e., mean scores for the IIEF “EF” domain and “Intercourse Satisfaction” domain). ^156^

Reports of five trials provided the treatment efficacy stratification analyses by ED origin (i.e., organic, psychogenic, and mixed). ^86,^ ^88,^ ^96,^ ^134,^ ^142^ The improvements in erectile function (mean scores for IIEF “EF” domain and percentage of patients who responded “yes” to GEQ-Q1) were observed regardless of the origin of ED in patients receiving sildenafil compared with those receiving placebo, without identifying the origin of ED as a treatment effect modifier or predictor.

Sildenafil dose/dosing 1 versus sildenafil dose/dosing 2. Six studies assessed the efficacy and harm profiles for different doses (i.e., 10 mg, 25 mg, 50 mg, and 100 mg) of sildenafil monotherapy. ^78,^ ^85,^ ^86,^ ^93,^ ^96,^ ^137^ Additionally, two other trials ^157,^ ^161^ examined and compared two different dosage regimens of sildenafil (i.e., fixed versus flexible, different timing of administration).

Harms. In one trial, ^137^ which reported the incidence of any adverse events, specifically, events in >5 percent of participants in one or more treatment groups, the proportions of participants experiencing at least one adverse event (due to all causes) in either the sildenafil 25 mg, 50 mg, and 100 mg treatment groups were 49, 61, and 72 percent, respectively. The corresponding dose-specific proportions observed in another trial, ^86^ a were 32, 69, and 86 percent, respectively. Both trials indicated a numerically increasing trend in the incidence of any adverse events observed with the higher dose of sildenafil. In one trial, ^96^ the proportion of patients with any adverse events (i.e., events in >5 percent of patients) observed in the 25 mg and 50 mg sildenafil groups were numerically higher (59 and 45 percent, respectively) compared with the 10 mg sildenafil group (24 percent). None of these three trials ^86,^ ^96,^ ^137^ reported any statistical test results for the observed between-treatment differences. In two trials, ^85,^ ^93^ the number of participants with treatment-related adverse events did not differ across the 25 mg and 50 mg sildenafil treatment groups. Of the events observed across the trials, ^78,^ ^85,^ ^86,^ ^93,^ ^96,^ ^137^ headache, myalgia, nausea, dyspepsia, and flushing were the most frequently experienced and were mild to moderate or transient in nature.

A total of four serious adverse events were reported in two studies. ^93,^ ^96^ These trials compared 25 mg to 50 mg, ^93^ and 10 mg to 25 mg and 50 mg of sildenafil. ^96^ One participant (4.7 percent) in the 25 mg sildenafil group discontinued the treatment because of pneumococcal pneumonia (the authors did not consider this a serious adverse event). ^93^ There were three other instances of serious adverse events (myocardial infarction, renal cell carcinoma, and epileptic crisis) in one trial. ^96^ The group designation of the participants experiencing these events were not reported.

Withdrawals due to adverse events were reported in five trials. ^85,^ ^86,^ ^93,^ ^96,^ ^137^ The rate of discontinuation ranged from 0 percent ^85^ to 3 percent ^96^ for the 10 mg dose of sildenafil, from 0 percent ^137^ to 4.7 percent ^93,^ ^96^ for the 25 mg dose, from 0 percent ^85^ a to 11 percent ^96^ for the 50 mg dose, and from 2 percent ^86^ a to 4 percent ^137^ for the 100 mg dose.

Safety data was not reported for the trial that compared different timing of sildenafil (100 mg) administration in relation to food and sexual activity. ^161^ In the trial ^157^ comparing “nightly” (50 mg) and “as needed” (50 mg to 100 mg) sildenafil dosing regimens, the proportion of withdrawals due to adverse events was similar across the two groups (approximately 7 percent). The authors of this trial did not report the incidence of any adverse events. Overall, more participants experienced adverse events (headache, flushing, dyspepsia, and rhinitis) in the “as needed” compared with the “nightly” group. Reportedly, none of the participants in this trial developed a serious adverse event. ^157^

Efficacy. All six trials ^78,^ ^85,^ ^86,^ ^93,^ ^96,^ ^137^ assessing the efficacy of different doses of sildenafil monotherapy (10 mg, 25 mg, 50 mg, and 100 mg), demonstrated a dose-response trend for sildenafil toward improving erectile function. Although none of these trials provided a formal statistical test for the observed between-arm (sildenafil versus placebo) differences, the degree of improvement tended to increase numerically with a higher dose of sildenafil. For example, the range for the mean IIEF Q-3 and Q-4 scores for three sildenafil dose arms in two trials ^86,^ ^137^ were as follows: 25 mg (Q-3: 3.18–3.20, and Q-4: 2.99–3.10), 50 mg (Q-3: 3.50–3.65, and Q-4: 3.50–3.64), and 100 mg (Q-3: 3.79–4.00 and Q-4: 3.63–3.90). The proportion of participants with an improved erection (based on GEQ-Q1) across four trials ^86,^ ^93,^ ^96,^ ^137^ ranged from 50 to 79 percent for 25 mg and from 52 to 88 percent for 50 mg sildenafil arms. In two trials, ^86,^ ^137^ the corresponding proportion of participants who received 100 mg sildenafil ranged from 84 to 88 percent. The authors of two trials, ^78,^ ^86^ reported dose-response treatment effects associated with administration of 25 mg, ^78,^ ^86^ 50 mg, ^78,^ ^86^ and 100 mg ^86^ of sildenafil with respect to mean scores for the IIEF “EF” domain (no numerical data provided; p <0.001) ^86^ and IIEF-Q1 (25 mg: 3.7, versus 50 mg: 4.5). ^78^ In two other trials ^85,^ ^93^ the participants' mean duration of penile rigidity (>80 percent and >60 percent, respectively) in minutes at the base and the tip of the penis was shown to increase numerically with higher doses of sildenafil (10 mg versus 25 mg versus 100 mg). In one trial, ^85^ the mean duration of penile rigidity at the base of the penis for participants receiving 10 mg sildenafil was 3.5 minutes (95 percent CI: 1.6–7.3). The ranges for the mean duration of penile rigidity (>60 percent or >80 percent) in two trials, ^85,^ ^93^ were 5.0 to 8.0 minutes (in participants receiving 25 mg sildenafil) and 10.1 to 11.2 minutes (in participants receiving 50 mg sildenafil). The proportions of participants who achieved grades 3–4 erections in the 25 mg, 50 mg, and 100 mg sildenafil groups were 72, 80, and 85 percent, respectively. ^86^ The mean number of erections per week (grades 3–4) was also shown to be numerically greater in two trials. ^93,^ ^96^ For example, the mean number of erections per week in one trial among participants who received 10 mg, 25 mg, and 50 mg sildenafil was 2.8, 3.0, and 3.6, respectively. ^96^

In two trials, ^157,^ ^161^ the efficacies of two different dosage regimens of sildenafil were compared. In one trial, ^157^ participants received either a fixed dose (50 mg every night) or a flexible dose (50 or 100 mg, as needed) of sildenafil for 12 months; in the other trial ^161^ participants were randomly assigned to receive 100 mg/d of sildenafil either 1 hour before/during a meal or 30–60 minutes before sexual activity. In the first trial, ^157^ the effect of a fixed dose of sildenafil given every night was maintained to a greater extent compared with that achieved with a flexible dosage of sildenafil. Specifically, the proportion of patients with a normal IIEF score (i.e., mean IIEF “EF” domain score ≥26) at 12 months in the two treatment groups (the “fixed 50 mg nightly” arm versus the “50–100 mg, as needed” arm), was similar (66.7 versus 67.3 percent, respectively); however, the corresponding proportions for the two groups after 1 month of post-treatment followup were 60.4 percent (95 percent CI: 45.3–74.2) versus 8.2 percent (95 percent CI: 2.3–19.6) in favor of nightly dosage group. The 13-month (i.e., one month after the 12-month treatment stopped) end-point mean peak systolic velocity (PSV) values for participants in the “nightly” and “as needed” groups were 37.0 (SD = 10.4) cm/s versus 26.5 (SD = 8.9) cm/s, respectively, favoring the “nightly” group. In the other trial, ^161^ the time between sildenafil administration and intercourse attempt (0–0.5 to >10 hours) had no statistically significant effect on the mean IIEF “EF” domain score and the proportion of intercourse attempts (based on SEP-Q2; p = 0.56), however, a longer period of time between taking sildenafil and intercourse attempt was associated with a statistically significant reduction in successful intercourse attempts (based on SEP-Q3; 92.8 percent at 1.5–2 hours versus 81.6 percent at >10 hours; p = 0.003). No statistically significant differences were observed for EDITS scores between the study arms (p >0.80). ^161^

Sildenafil monotherapy versus sildenafil in combination. This review included nine trials ^104^ – ^106,^ ^112,^ ^150,^ ^158,^ ^162,^ ^169,^ ^173^ in which the efficacy and harm of mono- versus combination therapy of sildenafil were compared. In these trials, sildenafil was used in combination with PLC and acetyl-L-carnitine (ALC), ^104^ intranasal PT-141, ^105^ psychotherapy, ^106^ propionyl-L-carnitine (PLC), ^112^ dihydro-ergotamine (DHE), ^150^ cabergoline, ^162^ atorvastatin, ^158,^ ^169^ quinapril, ^158^ and alfuzosin. ^173^

Harms. In general, harms were poorly reported in four trials. ^106,^ ^150,^ ^158,^ ^169^ The incidence of any adverse events were reported in only one ^162^ of the nine trials. ^104^ – ^106,^ ^112,^ ^150,^ ^158,^ ^162,^ ^169,^ ^173^ This study reported a higher proportion of participants with one or more adverse events in the combination arm (cabergoline and sildenafil) compared with the sildenafil monotherapy arm (12.2 versus 2.0 percent, p = 0.001). ^162^ In two trials no serious adverse events were reported during the trial period. ^112,^ ^173^ The remaining seven studies did not report serious adverse events. ^104^ – ^106,^ ^150,^ ^158,^ ^162,^ ^169^

Five studies reported information regarding withdrawals due to adverse events. ^104,^ ^105,^ ^112,^ ^162,^ ^173^ There were no withdrawals due to adverse events in three of these trials in any of the compared treatment groups, ^81,^ ^105,^ ^112^ and two trials ^162,^ ^173^ reported higher rates of withdrawals in sildenafil combination therapy than in sildenafil monotherapy. These rates were 5.8 percent with sildenafil/cabergoline therapy compared with 1.0 percent in sildenafil monotherapy, ^162^ and 14.5 percent with sildenafil/alfuzosin therapy compared with 9.5 percent in sildenafil monotherapy. ^173^

Efficacy. In all nine trials, participants who received combination therapies, in comparison with those who received sildenafil alone, were shown to have experienced numerical or statistically significant improvements for mean IIEF (or IIEF-5) scores for the “EF domain” and individual Q1–Q15 items, ^104,^ ^106,^ ^158,^ ^162,^ ^169,^ ^173^ higher frequency of penetration and maintenance of erection (mean scores for IIEF-Q3/Q4), ^112,^ ^150,^ ^162,^ ^173^ improved mean duration of rigidity of the tip/base of the penis (≥60 percent), ^105^ and a greater proportion of participants with improved erection (positive responses to GEQ-Q1). ^112^ However, in three trials ^104,^ ^158,^ ^169^ there was no statistically significant difference between the combination therapy and monotherapy groups in mean PSV values ^104,^ ^158^ or the proportion of patients with improved erection (positive responses to GEQ-Q1). ^169^

Sildenafil versus other active treatment. This review included five trials in which the efficacy and harms for sildenafil and other active treatment were compared. ^106,^ ^124,^ ^132,^ ^155,^ ^173^ These therapies were psychotherapy, ^106^ continuous positive air pressure (CPAP), ^155^ phentolamine, ^124^ Ro70-0004 (i.e., α1A-adrenoceptor antagonist), ^132^ and alfuzosin. ^173^

Harms. Among these five trials, ^106,^ ^124,^ ^132,^ ^155,^ ^173^ the incidence of any adverse event was reported in only one, in which more participants were found to have experienced one or more adverse event in the 40 mg phentolamine treatment group as compared with the flexible-dose (25 mg to 100 mg) sildenafil treatment group (41.2 versus 33.3 percent). ^124^ More patients in the phentolamine group than in the sildenafil group experienced respiratory (17.6 versus 8.9 percent) and digestive (12.6 versus 9.8 percent) adverse events. The most frequent adverse events that occurred during the trial were headache and rhinitis. ^124^ In the phentolamine treatment group, three participants (2.5 percent) experienced serious adverse events, as compared with only one participant (0.8 percent) in the sildenafil treatment group. These events were flushing, chest pain, shortness of breath with tachycardia in one participant, and cerebrovascular event and worsening of existing pterygium in the other two participants. One participant in the sildenafil treatment group experienced a rupture of the Achilles tendon. ^124^

The rate of withdrawals due to adverse events was reported in two trials, ^124,^ ^173^ in which it was higher among participants receiving phentolamine ^124^ or alfuzosin ^173^ than among those receiving sildenafil alone. The rates of withdrawals due to adverse events in participants treated with sildenafil in two trials were <1.0 percent ^124^ and 9.5 percent. ^173^ The corresponding rates for participants treated with phentolamine and alfuzosin were 3.4 percent ^124^ and 10 percent, ^173^ respectively.

Efficacy. In two trials ^124,^ ^155^ sildenafil use was associated with a statistically significant increase in the proportion of successful intercourse attempts, the mean IIEF “EF” domain score, and improved erections (GEQ-Q1), in comparison with the use of CPAP ^155^ and phentolamine. ^124^ In two other trials, ^132,^ ^173^ administration of sildenafil resulted in only numerical improvement in the mean duration of rigidity at the base/tip of the penis (>60 percent), ^132^ mean IIEF scores for the “EF domain,” as well as the frequency of penetration/maintenance of the erection (mean scores for IIEF-Q3/Q4), ^173^ in comparison with treatment with Ro70-0004 ^132^ or alfuzosin. ^173^ In one trial, ^106^ post-treatment mean IIEF scores were lower among those treated with sildenafil in comparison with those treated with psychotherapy, but the statistical significance was marginal (52.8 versus 62.5, p = 0.049).

### Quantitative Synthesis - Meta-analysis of Trials

Monotherapy (any dose: 10, 25, 50, 100 mg) versus placebo. In 62 trials the efficacy and harm-related effects of sildenafil compared with placebo in the treatment of ED were investigated. ^78^ – ^91,^ ^93^ – ^99,^ ^101,^ ^102,^ ^104,^ ^105,^ ^107^ – ^111,^ ^115,^ ^122,^ ^123,^ ^125,^ ^126,^ ^128,^ ^130^ – ^135,^ ^137,^ ^138,^ ^142,^ ^143,^ ^146,^ ^147,^ ^149,^ ^151,^ ^156,^ ^160,^ ^164,^ ^168,^ ^171,^ ^175^

The quantitative analysis was considered separately for two groups of trials (n = 62), as follows:

Trials conducted in clinically heterogeneous groups of participants with ED (with no established specific organic cause) (n = 34)

Trials conducted in clinically homogenous groups of participants with ED (participants diagnosed additionally with specific clinical conditions (2a-2e) (n = 28) The 34 clinically heterogenous trials were potentially eligible for the meta-analyses (24 parallel-arm and 10 crossover). ^80,^ ^82,^ ^83,^ ^85^ – ^90,^ ^95^ – ^97,^ ^105,^ ^110,^ ^111,^ ^122,^ ^125,^ ^126,^ ^130,^ ^132,^ ^134,^ ^135,^ ^137,^ ^138,^ ^142,^ ^146,^ ^149,^ ^151,^ ^156,^ ^166,^ ^171^ None of the 10 crossover trials ^85,^ ^89,^ ^105,^ ^130,^ ^132,^ ^134,^ ^146,^ ^149^ however, were incorporated in the meta-analyses (pre-crossover phase data were not reported), leaving 24 trials for further consideration. ^80,^ ^82,^ ^83,^ ^86^ – ^88,^ ^90,^ ^95^ – ^97,^ ^110,^ ^111,^ ^122,^ ^125,^ ^126,^ ^135,^ ^137,^ ^138,^ ^142,^ ^151,^ ^156,^ ^166,^ ^171^

Efficacy. Absolute endpoint mean IIEF “EF” domain score. The meta-analysis was based on two trials. ^88,^ ^126^ The pooled estimate of mean difference was 6.39 (95 percent CI: 2.89–9.90), indicating a statistically significant improvement in the mean IIEF “EF” domain score for participants receiving sildenafil (any dose) compared with those receiving placebo (Figure 3).

Absolute endpoint mean IIEF-Q3/Q4 scores. The two meta-analyses yielded statistically significant pooled estimates of mean differences for both IIEF-Q3 (mean difference 1.46, 95 percent CI: 1.26–1.65) and IIEF-Q4 (mean difference 1.52, 95 percent CI: 1.21–1.82). Thus, the use of sildenafil was associated with statistically significant improvements with respect to penetration and erectile maintenance frequency (Figures 4–5).

Figure 4 The mean IIEF-Q3 score

Figure 5 The mean IIEF-Q4 score

Proportion of participants with improved erection (GEQ-Q1). This meta-analysis included 17 trials including two trials reported in Young et al. (2002). ^80,^ ^82,^ ^83,^ ^86^ – ^88,^ ^90,^ ^95,^ ^97,^ ^125,^ ^126,^ ^137,^ ^138,^ ^142,^ ^151,^ ^156^ The pooled estimate of relative risk (RR) of 2.61 (95 percent CI: 2.34–2.91) indicated a greater proportion of participants experiencing improved erection (i.e., those who answered “yes” to GEQ-Q1) in the sildenafil than in the placebo treatment groups (Figure 6).

Figure 6 Improved erection (GEQ-Q1)

Sensitivity analysis was performed with respect to the duration of sildenafil treatment. The duration of sildenafil treatment in 11 trials lasted 12 weeks. ^80,^ ^83,^ ^87,^ ^97,^ ^125,^ ^126,^ ^137,^ ^138,^ ^142,^ ^151,^ ^156^ The duration of treatment in the remaining trials was 6 weeks, ^90^ (studies a and b) 8 weeks, ^82^ 16 weeks, ^95^ and 26 weeks. ^86,^ ^88^ The meta-analysis restricted to trials with 12-week treatment did not appreciably affect the magnitude of the effect estimate and the degree of I^2^ test for heterogeneity, which decreased from 51.9 percent to 50.0 percent.

Harms. 24 trials (including trials with participants with psychogenic ED), ^96,^ ^110^ were considered for the meta-analysis of adverse events. ^80,^ ^82,^ ^83,^ ^86^ – ^88,^ ^90,^ ^95^ – ^97,^ ^110,^ ^111,^ ^122,^ ^125,^ ^126,^ ^135,^ ^137,^ ^138,^ ^142,^ ^151,^ ^156,^ ^166,^ ^171^ (note that “favors” in forest plots refers to increased frequency of the event for the respective treatment arm, regardless of the desirability of the event).

Proportion of participants with at least one adverse event (all cause). The pooled estimate of RR suggested that participants randomly assigned to receive sildenafil were at a higher risk of developing any all-cause adverse event than those receiving placebo (RR = 1.51, 95 percent CI: 1.32–1.72) (Figure 7).

Figure 7 Any adverse events (all cause)

Proportion of participants with at least one adverse event (treatment-related). This meta-analysis incorporated 11 trials. ^80,^ ^82,^ ^83,^ ^87,^ ^90,^ ^97,^ ^125,^ ^135,^ ^137,^ ^156^ The meta-analysis yielded a pooled RR of 2.56 (95 percent CI: 2.17–3.03), indicating that participants randomly assigned to receive sildenafil were at a higher risk of developing any treatment-related adverse event than those receiving placebo (Figure 8).

Figure 8 Any adverse events (treatment-related)

Proportion of participants with headache (all cause). This meta-analysis was based on 16 trials. ^80,^ ^82,^ ^83,^ ^86^ – ^88,^ ^95^ – ^97,^ ^122,^ ^125,^ ^126,^ ^137,^ ^142,^ ^151,^ ^166^ The pooled estimate of RR indicated that participants randomly assigned to receive sildenafil were at a higher risk of having a headache than those receiving placebo (RR = 2.57, 95 percent CI: 2.09–3.18) (Figure 9).

Figure 9 Headache (all cause)

Proportion of participants with flushing (all cause). This meta-analysis is based on 16 trials. ^80,^ ^82,^ ^83,^ ^86^ – ^88,^ ^95^ – ^97,^ ^122,^ ^125,^ ^126,^ ^137,^ ^142,^ ^151,^ ^166^ The meta-analysis yielded a pooled RR of 5.34 (95 percent CI: 3.32–8.58), indicating that participants randomly assigned to receive sildenafil were at a higher risk of having flushing than those receiving placebo (Figure 10).

Figure 10 Flushing (all cause)

Proportion of participants with visual disturbances. This meta-analysis is based on 20 trials. ^80,^ ^82,^ ^83,^ ^86^ – ^88,^ ^90,^ ^95,^ ^97,^ ^122,^ ^125,^ ^126,^ ^135,^ ^137,^ ^138,^ ^142,^ ^151,^ ^156,^ ^171^ The pooled estimate of RR suggested that participants randomly assigned to receive sildenafil had a statistically significant greater risk of developing visual disturbances than those receiving placebo (RR = 3.66, 95 percent CI: 2.27–5.92) (Figure 11).

Figure 11 Visual disturbances (all cause)

Twenty-eight trials of clinically homogenous groups compared the efficacy/safety of sildenafil to that of placebo in patients with distinct, specific clinical conditions. ^78,^ ^79,^ ^81,^ ^84,^ ^91,^ ^93,^ ^94,^ ^98,^ ^99,^ ^101,^ ^102,^ ^104,^ ^107^ – ^109,^ ^115,^ ^123,^ ^128,^ ^131,^ ^133,^ ^143,^ ^147,^ ^160,^ ^164,^ ^165,^ ^167,^ ^168,^ ^175^ Of these, 13 trials were single trials per disease and were not considered further for meta-analysis. Thus, 15 trials were deemed as potentially eligible for the meta-analyses. The trials were conducted in participants diagnosed with diabetes, ^81,^ ^93,^ ^94,^ ^98,^ ^101^ depression, ^79,^ ^91,^ ^115,^ ^167^ congestive chronic heart failure, ^102,^ ^109^ hypertension, ^143,^ ^147^ or who were on dialysis. ^108,^ ^123^

Four trials with patients with diabetes could be pooled ^81,^ ^94,^ ^98,^ ^101^ with respect to IIEF-Q3/Q4, GEQ-Q1, and treatment-related adverse events. The meta-analyses were based on trials involving patients with Type I and Type II diabetes combined, as well as trials involving only patients with Type II (Figures 12–17).

Figure 13 Improved erection (GEQ-Q1): Type II diabetes

Figure 14 The mean IIEF-Q3 score: Type I-II diabetes

Figure 12 Improved erection (GEQ-Q1): Type I-II diabetes

Figure 17 Any adverse events (treatment-related): Type II diabetes

Efficacy. Proportion of participants with improved erection, GAQ-Q1, mean IIEF-Q3/4 score. The pooled effect estimates of meta-analyses of diabetic patients were all statistically significant, favoring the use of sildenafil over that of placebo to improve the erection (GEQ-Q1) in both Type I and II (RR = 4.25; 95 percent CI: 2.60– 6.93) as well as only in Type II patients, (RR = 5.33, 95 percent CI: 3.89–7.29). The pooled effect estimates for penile penetration ability (IIEF-Q3) (WMD: 1.03, 95 percent CI: 0.34–1.73) and erectile maintenance frequency (IIEF-Q4) (WMD: 1.15, 95 percent CI: 0.74–1.55) were also statistically significant in favor of sildenafil (Figures 12–15).

Figure 15 The mean IIEF-Q4 score: Type I-II diabetes

Harms. Proportion of participants with at least one treatment related adverse event. In the meta-analysis of combined Type I and Type II diabetes patients, a high degree of heterogeneity was found (I^2^ = 72.2 percent) (Figure 16). To explore the source of this heterogeneity, a sensitivity analysis was performed with respect to Type I and Type II diabetes. The meta-analysis based on Type II diabetes patients yielded a lower degree of heterogeneity (I^2^ = 24.4 percent), and the pooled effect estimate of the meta-analysis suggested that participants receiving sildenafil had a statistically significant increased risk of having any treatment-related adverse event in comparison with those receiving placebo (RR = 9.08, 95 percent CI: 4.01–20.54) (Figure 17).

Figure 16 Any adverse events (treatment-related): Type I-II diabetes

Four trials compared sildenafil to placebo in participants with depression. ^79,^ ^91,^ ^115,^ ^167^ Of these, three trials ^91,^ ^115,^ ^167^ involved participants with major depressive disorder (MDD) in remission. In two of these trials, ^91,^ ^167^ participants had ED associated with the use of antidepressants, namely, selective serotonin reuptake inhibitors (SSRIs). In the third trial, ^115^ about 28 percent of the participants used SSRIs. The three trials ^91,^ ^115,^ ^167^ were deemed to be potentially combinable. Given that the fourth trial ^79^ looked at ED patients who had depression but were not being treated with antidepressants at the time of their enrollment (this being one of the exclusion criteria), SSRI use could not be considered the cause of the ED, and the trial was therefore not combined with the other three for meta-analysis. ^91,^ ^115,^ ^167^

The results for the following efficacy outcomes (i.e., numerical effect estimates and standard deviations [SDs]) were ascertained from the three trials: percentage of successful intercourse attempts, ^115,^ ^167^ patients with improved erection (GEQ-Q1), ^115,^ ^167^ and mean IIEF-Q3/Q4 score. ^91,^ ^115^ The mean IIEF-Q3/Q4 scores and the corresponding SDs were ascertained graphically from one trial. ^115^ Separate meta-analyses for these efficacy outcomes are presented (see Figures 16–19). No meta-analysis for adverse events could be performed, due to a lack of sufficient detail for the adverse events definitions provided in the trials. Note that one trial ^91^ included younger patients (mean: 45, range 18–55 years) compared with the other trial (mean: 53, range 24–75 years). ^115^

Figure 19 Improved erection (GEQ-Q1): major depressive disorder in remission

Efficacy. Percentage of successful intercourse attempts, proportion of patients with improved erection, mean IIEF-Q3/Q4 score.

The pooled effect estimates of meta-analyses based on participants with depression were statistically significant, favoring the use of sildenafil over placebo with respect to: increasing the percentage of successful intercourse attempts (RR = 2.44, 95 percent CI: 1.87–3.18); improving erection, GEQ-Q1 (RR = 2.40, 95 percent CI: 1.87–3.06); improving penile penetration ability, IIEF-Q3 (mean difference 1.26, 95 percent CI: 0.82–1.70); and improving erectile maintenance frequency, as assessed by IIEF-Q4 (mean difference 1.48, 95 percent CI: 0.96–1.99) (Figures 18–21).

Figure 18 Successful intercourse attempts: major depressive disorder in remission

Figure 21 The mean IIEF-Q4 score: major depressive disorder in remission

Two sildenafil versus placebo trials conducted in participants with chronic congestive heart failure (CHF) were potentially combinable. ^102,^ ^109^ However, no meta-analysis was performed in view of the fact that the only common outcome reported in both trials was the mean IIEF “EF” domain score, for which numerical values of the measures of variability—SD or standard error (SE) could not be ascertained. One of the trials ^102^ used a crossover design; it reported pre-crossover results graphically, without presenting numeric measures of the variability. In the same trial, no participant had any adverse events; therefore, no meta-analysis for adverse events was performed.

There were two trials that looked at patients with chronic renal failure on peritoneal dialysis. Although they were both eligible for meta-analysis (with respect to the mean IIEF “EF” domain score), ^108,^ ^123^ they could not be pooled in view of a lack of complete numerical data (i.e., a SD or SE) in one of the trials. ^108^ A meta-analysis for adverse events was also not feasible, since in one of the trials ^108^ only one event was observed.

Meta-analysis was possible for sildenafil versus placebo trials involving hypertensive patients using multiple antihypertensive drugs (i.e., two or more different classes). ^143,^ ^147^ The meta-analyses were performed for efficacy outcomes (i.e., mean IIEF-Q3/Q4, GEQ-Q1, percentage of successful intercourse attempts) as well as all-cause and treatment-related specific adverse events (headache, flushing, and dyspepsia) (Figures 22–29).

Figure 22 The mean IIEF-Q3 score: patients with hypertension taking anti-hypertensive drugs

Figure 29 Flushing (treatment-related): patients with hypertension taking anti-hypertensive drugs

Efficacy. Mean IIEF-Q3/Q4, GEQ-Q1, percentage of successful intercourse attempts.

The mean IIEF-Q3/Q4 scores with respective SDs were ascertained from the reports of both trials, as well as for GEQ-Q1, along with the percentage of successful intercourse attempts (see Figures 20–23). The pooled effect estimates indicate a statistically significant improvement in patients receiving sildenafil in comparison with those receiving placebo with respect to: improving penile penetration ability, IIEF-Q3 (mean difference 1.09, 95 percent CI: 0.59–1.58); erectile maintenance frequency, IIEF-Q4 (mean difference 1.34, 95 percent CI: 0.75–1.93); erection, as assessed by GEQ-Q1 (RR = 3.07, 95 percent CI: 1.81–5.19); and percentage of successful intercourse attempts (RR = 2.41, 95 percent CI: 1.99–2.92) (Figures 22–25).

Figure 20 The mean IIEF-Q3 score: major depressive disorder in remission

Figure 23 The mean IIEF-Q4 score: patients with hypertension taking anti-hypertensive drugs

Figure 25 Successful intercourse attempts: patients with hypertension taking anti-hypertensivedrugs

A high degree of heterogeneity with respect to the proportion of patients with improved erection (GEQ-Q1) was present across the two trials (I^2^ = 83.2 percent) (Figure 24). Although the effect size for the two estimates of the RR was in the same direction, the magnitude of this effect differed between the two trials (2.33 ^143^ versus 3.94 ^147^ ). One explanation of this finding could be the disparate rates of improvement on GEQ observed in the placebo arms of these trials (29 percent ^143^ versus 18 percent ^147^ ). Note that the respective rates in the sildenafil arms were quite similar (73 percent versus 71 percent). The higher rate of improvement on GEQ for the placebo arm in the first trial ^143^ resulted in the smaller effect size (RR = 2.33). This could be explained by a higher proportion of participants with a mild to moderate form of ED, which may have resulted from the difference between the two trials in with respect to the use of inclusion criteria based on IIEF scores (≤25 ^143^ versus ≤21 ^147^ ). Moreover, other contributing factors for the observed differences for the improvement rates between the two placebo arms could have been due to the fewer patients with organic ED (18 percent ^143^ versus 51 percent ^147^ ) and a shorter mean duration of ED in the first trial (2.2 years ^143^ versus 4.5 years ^147^ ). The two trials employed similar dosing regimens (from 50 mg to 25 mg or 100 mg) and duration of sildenafil treatment (6–8 weeks). ^143,^ ^147^

Figure 24 Improved erection (GEQ-Q1): patients with hypertension taking anti-hypertensive drugs

Harms. Incidence of any adverse event: headache, dyspepsia, flushing.

The pooled RR estimates showed a statistically significant increase in risk among participants treated with sildenafil compared with those receiving placebo for all-cause adverse events (RR = 1.72, 95 percent CI: 1.33–2.24) and for the treatment-related specific events such as headaches (RR = 6.32, 95 percent CI: 1.92–20.85), dyspepsia (RR = 8.31, 95 percent CI: 1.54–44.86), and flushing (RR = 7.10, 95 percent CI: 1.58–31.95) (Figures 26–29).

Figure 27 Headache (treatment-related): patients with hypertension taking anti-hypertensive drugs

Figure 28 Dyspepsia (treatment-related): patients with hypertension taking anti-hypertensive drugs

Figure 26 Any adverse event (all cause): patients with hypertension taking anti-hypertensive drugs

Meta-analysis of trials comparing different doses of sildenafil (dose-response effect). The dose-response efficacy/harm effect of sildenafil given at a fixed dose (10 mg, 25 mg, 50 mg, and 100 mg) was assessed in six trials. ^78,^ ^85,^ ^86,^ ^93,^ ^96,^ ^137^ Of these, two trials were conducted in clinically distinct groups of participants (those with spina bifida ^78^ and diabetes ^93^ ) and therefore were not included in the meta-analysis. Therefore, the meta-analysis exploring the dose-response effect of sildenafil was based on three trials. ^86,^ ^96,^ ^137^

The following two pair-wise comparisons were made:

1) Sildenafil 25 mg versus sildenafil 50 mg
2) Sildenafil 50 mg versus sildenafil 100 mg

The efficacy and harm outcomes examined in the meta-analysis (i.e., those assessed and reported in sufficient detail in all three trial reports) were the proportions of participants with improved erection (GEQ-Q1) and the proportions of participants who experienced a specific all-cause adverse event (i.e., headache, flushing, or visual disturbances) (Figures 30–37).

Figure 30 Improved erection (GEQ-Q1)

Figure 37 Visual disturbances (all cause)

Sildenafil 25 mg versus sildenafil 50 mg - Efficacy. Proportion of participants with improved erection (GEQ-Q1). A statistically significant greater proportion of participants in the 50 mg sildenafil treatment group reported improved erection (GEQ-Q1) in comparison with the 25 mg group (RR = 1.19, 95 percent CI: 1.06–1.34) (Figure 30).

Sildenafil 25 mg versus sildenafil 50 mg - Harms. Proportion of participants with headache, flushing, or visual disturbances.

The pooled estimates for the observed between-group (50 mg sildenafil versus 25 mg sildenafil) differences with respect to proportions of participants experiencing all-cause headaches (RR = 1.02, 95 percent CI: 0.69–1.50) and visual disturbances (RR = 2.87, 95 percent CI: 0.70–11.80) were not statistically significant (Figures 31 and 33). The latter result may have been due to the small sample of the meta-analysis (Figure 31). The incidence of all-cause flushing was significantly greater among participants receiving the higher 50 mg dose of sildenafil (RR = 1.65, 95 percent CI: 1.13–2.42) (Figure 32).

Figure 31 Headache (all cause)

Figure 32 Flushing (all cause)

Figure 33 Visual disturbances (all cause)

Sildenafil 50 mg versus sildenafil 100 mg - Efficacy. Proportion of patients with improved erection.

The difference in the proportion of participants with improved erection (i.e., those who answered “yes” to GEQ-Q1) between the 50 mg and 100 mg sildenafil treatment groups was not statistically significant (RR = 1.10, 95 percent CI: 1.00–1.20) (Figure 34).

Figure 34 Improved erection (GEQ-Q1)

Sildenafil 50 mg versus sildenafil 100 mg - Harms.

Proportion of patients with all-cause headache, flushing, or visual disturbances. There was no statistically significant difference between the 100 mg and 50 mg sildenafil treatment groups in the incidence of all-cause headaches (RR = 1.31, 95 percent CI: 0.93–1.84), flushing (RR = 0.87, 95 percent CI: 0.61–1.23), and visual disturbances (RR = 4.18, 95 percent CI: 0.44– 39.54) (Figures 35–37).

Figure 36 Flushing (all cause)

Figure 35 Headache (all cause)

### Assessment of Publication Bias

Funnel plots were generated to assess the extent of asymmetry for each meta-analysis. Visual inspection of these plots did not reveal any substantial asymmetry. ^53^ (Figures D-1–8, Appendix D).

## Oral Treatments — Phosphodiesterase Type 5 (PDE-5) Inhibitors - Vardenafil

### Literature Search

In total, 22 unique randomized controlled trials (RCTs) (31 publications) met the eligibility criteria and were included in the review. ^180^ – ^210^ (see also summary Evidence Table F-2, Appendix F) Seven unique trials were reported in more than one publication. The following list shows the reference identifications for these trials and corresponding publications (each row).

The first reference (author, year, citation) denotes the primary publication (i.e., reporting the most relevant and complete data for the trial), which is used to designate the trial throughout the Vardenafil section.

1 Valiquette 2005 ^182^ and Valiquette 2006 ^202^
2 Nehra 2005 ^183^ and Brock 2003 ^187^
3 Carson 2005 ^184^ and Hatzichristou 2005 ^188^
4 Hatzichristou 2004 ^191^ and Hatzichristou 2005 ^207^
5 Porst 2001 ^194^ and Porst 2003 ^185^
6 Goldstein 2005 ^197^ and Fisher 2005 ^186^
7 Hellstrom 2002, ^192^ Hellstrom 2003, ^208^ Hellstrom 2005, ^209^ and Donatucci 2004 ^210^

### Overview of Trials

The trials were conducted in North America, ^181^ – ^184,^ ^190,^ ^190,^ ^192,^ ^192,^ ^197,^ ^197^ – ^199,^ ^199,^ ^203^ Europe, ^184,^ ^190,^ ^191,^ ^193^ – ^201,^ ^203,^ ^204^ South America, ^182,^ ^190,^ ^203^ and Asia. ^180,^ ^182,^ ^184,^ ^189,^ ^203,^ ^203,^ ^205,^ ^206^

Of the 22 trials, two were of crossover design ^193,^ ^195^ and the remaining 20 trials used parallel-arm design. All but one (active arm-controlled) ^190^ were placebo-controlled trials.

The trials were supported by Bayer ^181,^ ^183,^ ^189,^ ^190,^ ^192^ – ^195,^ ^197,^ ^198,^ ^200,^ ^201,^ ^203,^ ^205^ Bayer and GlaxoSmithKline, ^182,^ ^184,^ ^191,^ ^196,^ ^199^ and GlaxoSmithKline. ^204^ Funding sources could not be ascertained for two trials. ^180,^ ^206^

### Populations

The included trials involved participants diagnosed with ED. The total and mean numbers of patients randomly assigned to an intervention or placebo across the 22 trials were 8,621 and 392, respectively, while the number of randomly assigned patients in each trial ranged from 21 ^193^ to 1020. ^190^

The inclusion criteria across most of the included trials were: adult males aged ≥18 years, diagnosed with ED for ≥ 6 months in a stable monogamous heterosexual relationship. ^180^ – ^184,^ ^189^ – ^195,^ ^197^ – ^201,^ ^203,^ ^204^ In one trial, ^205^ the inclusion criteria for the patients' age and duration of ED were slightly different (≥20 and ≥5 years, respectively). In the report of one trial ^206^ the patient inclusion criteria for age and duration of ED were not clear.

The additional inclusion criteria in seven trials were diagnoses for the following conditions: diabetes types I or II, ^181,^ ^205^ diabetes type I, ^204^ nerve-sparing retropubic prostatectomy, ^183^ history of renal transplant, ^206^ untreated mild major depressive disorder, ^199^ or arterial hypertension. ^196^ One trial included ED patients who had not responded to previous sildenafil therapy. ^184^ In three trials, the included patients were sildenafil-naïve. ^180,^ ^201,^ ^204^ In one of these trials, ^180^ patients had not received any previous treatment for ED.

In most trials, patients had ED with a broad spectrum of causes (i.e., organic, psychogenic, and mixed). ^180,^ ^182,^ ^184,^ ^189^ – ^195,^ ^197,^ ^198,^ ^200,^ ^201,^ ^203^ The mean age across the 22 trials ranged from 34 years ^195^ to 60 years. ^183,^ ^184^

Exclusion criteria were not reported for two trials. ^180,^ ^200^ Patients with the following conditions were excluded from the trials: primary hypoactive sexual desire ^181^ – ^184,^ ^190^ – ^193,^ ^196^ – ^199,^ ^201,^ ^203^ – ^205^ penile/genital anatomical deformity, ^182,^ ^184,^ ^189^ – ^192,^ ^195^ – ^199,^ ^201,^ ^203,^ ^204,^ ^206^ any medical psychiatric or substance abuse disorder affecting the ability to complete the study, ^182,^ ^184,^ ^189,^ ^199,^ ^201,^ ^205^ ED resulting from spinal cord injury, ^181^ – ^184,^ ^189^ – ^199,^ ^201,^ ^203^ – ^205^ cardiovascular conditions (e.g. coronary artery disease, myocardial infarction, electrocardiographic ischemia, life-threatening arrhythmia, stroke, uncontrolled atrial tachyarrhythmia, unstable angina pectoris, uncontrolled atrial fibrillation), ^181^ – ^184,^ ^189^ – ^193,^ ^195^ – ^198,^ ^201,^ ^203^ – ^206^ hyper/hypotension (resting), ^181^ – ^184,^ ^189^ – ^193,^ ^195,^ ^196,^ ^201,^ ^203^ – ^206^ postural hypotension, ^182,^ ^183,^ ^189,^ ^192,^ ^196,^ ^201,^ ^204,^ ^205^ liver disease, ^181,^ ^183,^ ^189,^ ^191,^ ^192,^ ^196,^ ^198,^ ^201,^ ^204^ – ^206^ radical prostatectomy, ^190^ – ^199,^ ^201,^ ^203^ – ^205^ bleeding or hematological disorder, ^181,^ ^183,^ ^189,^ ^191,^ ^192,^ ^198,^ ^201,^ ^203,^ ^204,^ ^206^ retinitis pigmentosa, ^181^ – ^183,^ ^190,^ ^192,^ ^193,^ ^195^ – ^199,^ ^203^ – ^205^ poorly controlled diabetes mellitus, ^182,^ ^183,^ ^189^ – ^195,^ ^198,^ ^203^ hepatitis B, ^189,^ ^192,^ ^194,^ ^195,^ ^198,^ ^203^ hepatitis C, ^189,^ ^192,^ ^194,^ ^196,^ ^201,^ ^204^ peptic ulceration, ^183,^ ^189,^ ^192,^ ^201,^ ^205,^ ^206^ major psychiatric disorders, ^193,^ ^195,^ ^199^ endocrine diseases, ^193,^ ^195^ autonomic neuropathy, ^181^ or prostate cancer. ^183^

The following concomitant medications were not allowed: nitrates or nitric oxide donors, ^181^ – ^184,^ ^189,^ ^191^ – ^198,^ ^201,^ ^203^ – ^206^ cimetidine, erythromycin, ketoconazole or trazodone, current use of digoxin derivatives or digitoxin antiarrhythmics, ^189,^ ^192,^ ^194,^ ^196^ – ^198,^ ^201,^ ^204^ anticoagulants, ^181^ – ^183,^ ^192,^ ^194,^ ^196^ – ^198,^ ^201,^ ^204^ androgens, ^192,^ ^196^ – ^198,^ ^201,^ ^203,^ ^204^ ketoconazole, ^194,^ ^196,^ ^197,^ ^204^ alpha blockers, ^196^ – ^198,^ ^201^ or rifampicin. ^189,^ ^194^

Patients with abnormal hormone profiles such as low serum total testosterone, ^182^ – ^184,^ ^189,^ ^192,^ ^194,^ ^201,^ ^203^ elevated serum creatinine, ^184,^ ^189,^ ^192,^ ^196,^ ^201,^ ^203,^ ^204^ serum free thyroxine (T4) out of the normal range, ^189^ or thyroid-stimulating hormone (TSH) below the normal range were also excluded. ^189,^ ^194^

Also excluded were sildenafil nonresponders ^189^ – ^194,^ ^198,^ ^199,^ ^203^ and patients who had discontinued previous sildenafil treatment because of side effects. ^181,^ ^183,^ ^189^ – ^191,^ ^198^

### Interventions

The patients in all 22 included trials were randomly assigned to receive monotherapy of oral vardenafil at either a fixed or a flexible dose. In 12 trials, ^180^ – ^183,^ ^189,^ ^190,^ ^192^ – ^195,^ ^198,^ ^205^ vardenafil was administered at a fixed dose ranging from 5 mg/d ^189,^ ^192,^ ^194^ to 40 mg/d, ^193^ whereas in the remaining 10 trials a flexible dose with upward and downward titration was used, depending on the observed response in terms of efficacy and tolerability (i.e., 10 mg/d, 5 mg/d, 20 mg/d). ^184,^ ^191,^ ^196,^ ^197,^ ^199^ – ^201,^ ^203,^ ^204,^ ^206^

The patients were randomly assigned to receive placebo in all but one trial, ^190^ in which two doses (10 mg/d and 20 mg/d) of vardenafil were compared. In one trial the study medication (i.e., vardenafil) was coadministered with visual sexual stimulation. ^195^

In 10 trials patients were randomly assigned to receive two or more different fixed doses of vardenafil in each arm: 10 mg/d versus 20 mg/d, ^181,^ ^183,^ ^190,^ ^195,^ ^198,^ ^205^ 5 mg/d versus 10 mg/d versus 20 mg/d, ^189,^ ^192,^ ^194^ and 20 mg versus 40 mg. ^193^

In the majority of included trials, the duration of treatment with vardenafil was about 12 weeks. ^181^ – ^184,^ ^189,^ ^194,^ ^211^ The treatment duration across the trials ranged from 4 weeks ^198,^ ^206^ to 24 months. ^190^

Patients were instructed to take the study medication one hour before their sexual activity ^182^ – ^184,^ ^189^ – ^192,^ ^194,^ ^196,^ ^204^ – ^206^ or as needed ^181,^ ^198^ for maximum of one dose per day. In one trial patients were instructed to take the dose 8 hours before sexual activity for up to one dose a day. ^203^ Five trials did not report the dosage instructions clearly. ^180,^ ^197,^ ^199^ – ^201^

### Outcomes

Harms. The presence or absence of any adverse events was reported in eight trials. ^182^ – ^184,^ ^189,^ ^191,^ ^193,^ ^200,^ ^203^ The presence or absence of serious adverse events was reported in 18 trials. ^181^ – ^184,^ ^190^ – ^198,^ ^200,^ ^201,^ ^203^ – ^205^ The presence or absence of withdrawals due to adverse events was reported in 19 trials. ^181^ – ^184,^ ^189^ – ^199,^ ^201,^ ^203^ – ^205^

Efficacy. The most commonly reported outcomes that measured the degree of ED were: the mean IIEF scores for the “Erectile Function” domain (endpoint or mean change from baseline); ^181^ – ^184,^ ^189^ – ^192,^ ^194,^ ^196^ – ^201,^ ^203^ – ^206^ the mean endpoint score/mean score changes on questions two and three of the Sexual Encounter Profile (SEP-Q2: “Were you able to insert your penis into your partner's vagina?” and SEP-Q3: “Did your erection last long enough for you to have successful intercourse?”) ^181^ – ^184,^ ^190^ – ^192,^ ^196^ – ^201,^ ^203^ – ^205^ and a Global Assessment Question (GAQ-Q1: “Has the treatment you are taking improved your erection?”). ^181^ – ^184,^ ^189^ – ^192,^ ^196,^ ^199^ – ^201,^ ^203^

Other commonly reported outcomes were total mean scores for the following IIEF domains: “Intercourse Satisfaction,” ^183,^ ^194,^ ^198,^ ^204^ “Overall Satisfaction,” ^183,^ ^194,^ ^198,^ ^204^ “Orgasmic Function,” ^183,^ ^194,^ ^204^ “Sexual Desire,” ^194,^ ^204^ and the mean scores for individual IIEF questions Q3/Q4 (i.e., penetration and maintenance frequency). ^183,^ ^189,^ ^194,^ ^200,^ ^205^

Other less frequently reported outcomes were measured using the following instruments: Center for Epidemiologic Studies Depression Scale (CES-D), ^183,^ ^190,^ ^199^ the quality of life (QoL) Fugl-Meyer assessment, ^189,^ ^190,^ ^194^ the Rosenberg Self-Esteem Scale, ^199,^ ^200^ tip and base rigidity activity unit (RAU) and tumescence activity units (TAU), ^193,^ ^195^ the duration of erection with rigidity of >60 percent (or >80 percent), ^193,^ ^195^ patient's diary of satisfaction with erection/ejaculation, ^191^ ED severity, ^206^ endothelial function of cavernous and brachial arteries (flow mediated dilation: FMD), ^180^ and sexual quality of life domain from the modified Sexual Life Quality Questionnaire (mSLQQ). ^197^

### Study and Reporting Quality

The mean total Jadad score for the 22 trials was 3.3 (Appendix C, Table C-1). The Jadad total score for the individual trials ranged from one ^206^ to five. ^191,^ ^197^ The methods for generating the sequence of random assignment were described for four studies ^183,^ ^191,^ ^192,^ ^197^ and were judged to be appropriate. All trials except for one ^206^ were described as double-blind. For all trials except for one ^189^ the methods for treatment allocation concealment were judged to be “unclear.” The method of allocation concealment reported in the above-mentioned trial was deemed to be appropriate. ^189^ Both crossover trials ^193,^ ^195^ employed a washout period of five days.

### Qualitative Synthesis

Vardenafil (any dose, fixed dose, flexible dose) versus placebo. This section presents results derived from 21 placebo-controlled trials that compared the efficacy and harms profile of vardenafil (any dose) to that of placebo. ^180^ – ^184,^ ^189,^ ^191^ – ^201,^ ^203^ – ^206^ One trial190 that explored a dose-response effect of vardenafil, without using a placebo arm, is reviewed in a later section (vardenafil dose 1 versus vardenafil dose 2).

Harms. Of the 21 trials, harms-related data were reported in all but one. ^180^ Therefore, this section describes harms reported in 20 trials. ^181^ – ^184,^ ^189,^ ^191^ – ^201,^ ^203^ – ^206^

Any all-cause adverse events. This outcome was reported in eight trials, where it was shown that the incidence of any adverse events (number of patients with one or more adverse event), ^182^ – ^184,^ ^189,^ ^191,^ ^193,^ ^200,^ ^203^ was higher (either numerically or with statistical significance) in vardenafil groups (regardless of vardenafil dose or dose regimen) than in placebo groups. The proportions of patients with one or more adverse event in vardenafil groups across the trials ranged from about 27 percent (10 mg dose) ^182^ to 74 percent (20 mg dose). ^189^ The corresponding proportion for the placebo groups ranged from about 17 percent ^200^ to 52 percent. ^189^

Specific adverse events. In general, vardenafil was described as well tolerated. Most adverse events were reported as mild or moderate in nature and followed a profile similar to that seen in other medications of the PDE-5 class (e.g. sildenafil, tadalafil). Most commonly, patients in the vardenafil arms experienced headache, flushing, rhinitis, and dyspepsia.

Withdrawals due to adverse events. Two ^200,^ ^206^ of the 20 trials ^181^ – ^184,^ ^189,^ ^191^ – ^201,^ ^203^ – ^206^ did not report the proportion of withdrawals due to adverse events. Overall, the rate of withdrawals due to adverse events (i.e., the proportion of patients) in vardenafil and placebo-treated groups of patients were numerically similar. The withdrawal rate in vardenafil groups across the 18 trials ^181^ – ^184,^ ^189,^ ^191^ – ^199,^ ^201,^ ^203^ – ^205^ ranged from 0 percent ^193,^ ^195,^ ^198^ to 5 percent. ^192^ The corresponding rate for the placebo-treated patients ranged from 0 percent ^193,^ ^195,^ ^203^ to 6 percent. ^189^ Some of the reported specific events leading to the withdrawals were myocardial infarction, proctalgia, aortic bifurcation graft, ^212^ abnormal liver enzyme levels, ^182,^ ^192^ myalgia, flushing, ^181,^ ^182^ nausea, ^192^ headache, ^181,^ ^191,^ ^192^ kidney calculus, ^192^ abnormal vision, and rhinitis. ^181^

Serious adverse events. The absence or occurrence of serious adverse events could not be ascertained for three trials. ^189,^ ^199,^ ^206^ The specific serious adverse events observed across the trials in patients after random assignment to vardenafil therapy were: skin ulcer, ^198^ reflux disease, ^198^ unstable angina, ^197^ myocardial infarction, ^198,^ ^201^ syncope and encephalitis ^198^ aortic bifurcation, ^201^ facial palsy, and appendicitis. ^182^ Serious adverse events that occurred in 10 trials were not specified. ^181,^ ^183,^ ^184,^ ^191,^ ^192,^ ^194,^ ^196,^ ^203^ – ^205^ In three trials ^193,^ ^195,^ ^200^ reportedly no serious adverse events occurred. In general, judging from the results of these trials, there were no obvious numerical or statistical differences in the occurrence of serious adverse events between patients randomly assigned to receive vardenafil and those assigned to placebo.

Vardenafil (fixed dose: 5 mg, 10 mg, 20 mg, 40 mg) versus placebo. In 11 trials vardenafil was administered at a fixed dose (5 mg, 10 mg, 20 mg, and/or 40 mg). ^180^ – ^183,^ ^189,^ ^192^ – ^195,^ ^198,^ ^205^

The results of all trials demonstrated statistically significant improvements for patients who received vardenafil (5 mg, 10 mg or 20 mg) compared with those treated with placebo after 12 weeks of treatment (or longer followup) with respect to the mean IIEF scores for the “EF domain,” ^181^ – ^183,^ ^189,^ ^192,^ ^194,^ ^198,^ ^205^ IIEF-Q3/Q4, ^189,^ ^194^ SEP-Q2/Q3, ^181,^ ^182,^ ^192,^ ^198,^ ^205^ GAQ-Q1, ^181,^ ^182,^ ^189,^ ^192,^ ^194^ and the mean IIEF scores for the domains of “Intercourse Satisfaction,” “Overall Satisfaction,” “Sexual Desire,” and “Orgasmic Function.” ^183,^ ^194^

Results obtained from two trials ^193,^ ^195^ showed a statistically significant increase in the mean duration (in minutes) of penile tip/base rigidity (>60 percent) in patients randomly assigned to receive vardenafil at a dose of 10 mg, ^195^ 20 mg, ^193,^ ^195^ or 40 mg, ^193^ as compared with those randomly assigned to receive placebo.

In one trial, ^180^ patients treated with vardenafil (20 mg), in comparison with those treated with placebo, experienced a statistically significant improvement in endothelial function measured by the degree of brachial artery flow-mediated dilation (13.0 percent versus 10.7 percent).

The beneficial effects of vardenafil use relative to that of placebo observed in trials of homogeneous clinical groups such as diabetes, ^181,^ ^205^ nerve-sparing retropubic prostatectomy, ^183^ and no previous ED treatment ^180^ were consistent with those of other trials conducted in participants with ED and a wide spectrum of diseases. ^182,^ ^189,^ ^192^ – ^195,^ ^198^

Treatment efficacy subgroup analyses (i.e., stratified efficacy results) were reported for five trials with respect to the origin of ED, ^180,^ ^194^ baseline severity of ED, ^182,^ ^192,^ ^194^ age groups, ^194^ and previous sildenafil use. ^194,^ ^198^ The results of these analyses indicated numerically greater improvements associated with milder forms of ED, ^192,^ ^194^ no previous use of sildenafil (i.e., sildenafil-naïve patients), ^198^ and arteriogenic ED (versus organic nonarterial or psychogenic ED). ^180^ In one of these trials, ^194^ the degree of improvement in IIEF “EF” domain scores was not modified by age, previous sildenafil use or the origin of ED (organic, mixed, or psychogenic).

Vardenafil (flexible dose: 5 mg- 10 mg- 20 mg) versus placebo. Ten trials administered vardenafil with a flexible daily dose (5 mg, 10 mg, 20 mg). ^184,^ ^191,^ ^196,^ ^197,^ ^199^ – ^201,^ ^203,^ ^204,^ ^206^ The results of all trials demonstrated statistically significant improvements for patients receiving a flexible dose of vardenafil compared with those treated with placebo after 12 weeks of treatment (or longer followup) with respect to the mean IIEF scores for “EF domain,” ^184,^ ^191,^ ^197,^ ^199^ – ^201,^ ^203,^ ^204,^ ^206^ IIEF-Q3/Q4, ^200,^ ^206^ SEP-Q2/Q3, ^184,^ ^191,^ ^196,^ ^197,^ ^199^ – ^201,^ ^203,^ ^204^ and GAQ-Q1. ^184,^ ^191,^ ^196,^ ^199^ – ^201,^ ^203^ Statistically significant improvements in vardenafil-treated patients, relative to those on placebo, were also observed with respect to mean scores for the following IIEF domains: “Intercourse Satisfaction,” “Overall Satisfaction,” “Orgasmic Function” ^199,^ ^200^ and/or “Sexual Desire.” ^199,^ ^204^

In four trials, ^184,^ ^201,^ ^203,^ ^204^ at followup after 12 weeks of treatment, a statistically significant greater proportion of patients with an IIEF “EF” domain score ≥26 was found in groups treated with vardenafil compared with those who received placebo.

The relative beneficial effects of vardenafil use with respect to the above-mentioned outcomes observed in trials of homogeneous clinical groups, such as patients with diabetes, ^204^ renal transplant, ^206^ untreated mild major depressive disorder, ^199^ or arterial hypertension, ^196^ as well as sildenafil nonresponders ^184^ and sildenafil- naïve patients ^201,^ ^204^ were consistent with those of other trials conducted in participants with ED and a wide spectrum of diseases. ^191,^ ^197,^ ^200,^ ^203^

Treatment efficacy subgroup analysis (i.e., stratified efficacy results) was reported for only one trial ^191^ with respect to dose-sequence, in which patients who received a stable dose of 10 mg vardenafil over 12 weeks experienced greater improvements on the mean scores for IIEF “EF domain,” SEP-Q2/Q3, and the proportion for GAQ-Q1 compared with those who gradually increased their vardenafil dose to 20 mg over the followup of 8 weeks.

Vardenafil dose 1 versus vardenafil dose 2. There were 10 trials with two or more dose-specific arms of vardenafil. ^181,^ ^183,^ ^189,^ ^190,^ ^192^ – ^195,^ ^198,^ ^205^ None of the trials were designed to compare flexible and fixed dosage regimens of vardenafil.

Harms. Any all-cause adverse events.

In seven ^183,^ ^189,^ ^190,^ ^192,^ ^193,^ ^195,^ ^205^ of the 10 dose-response studies, ^181,^ ^183,^ ^189,^ ^190,^ ^192^ – ^195,^ ^198,^ ^205^ the incidence of any adverse events was shown to be numerically dose-dependent, increasing with a higher dose. In one multicenter North American study, for example, after 26 weeks of treatment with 5 mg, 10 mg, or 20 mg of vardenafil or placebo 19, 33, 42 and 7 percent of patients, respectively, experienced at least one adverse event. ^192^ In a trial of similar design of 12 weeks' duration, these proportions were 57, 63, 74, and 52 percent, respectively. ^189^ The similar trend was observed in a trial that compared 20 mg and 40 mg doses of vardenafil (47.6 versus 60.9 percent, respectively). ^193^ Statistical test results for these differences were not reported.

Specific adverse events. The most frequently observed adverse events in the 10 trials were headache, flushing, dyspepsia, or rhinitis. In one trial, ^190^ eight and 13 patients developed visual disturbance(s) in the 10 mg and 20 mg groups, respectively. In another trial, ^189^ two patients (one patient in each 5 mg and 20 mg groups) were observed to have visual disturbances (sensory, abnormal vision, and brightening).

Withdrawals due to adverse events. In three trials, ^193,^ ^195,^ ^198^ none of the patients treated with vardenafil withdrew because of adverse events. For the remaining seven trials, ^181,^ ^183,^ ^189,^ ^190,^ ^192,^ ^194,^ ^205^ the rate of withdrawals was numerically similar between treatment arms using 10 mg versus 20 mg of vardenafil. ^181,^ ^183,^ ^189,^ ^190,^ ^192,^ ^194,^ ^205^

Serious adverse events. There was no apparent numerical or statistically significant difference in the occurrence of serious adverse events across the treatment arms of various doses of vardenafil. For example, one trial reported 4, 1, and 1.4 percent of patients with at least one serious adverse event in 5 mg, 10 mg, and 20 mg vardenafil groups, respectively. ^194^ In another study, the corresponding proportions of patients with at least one serious adverse event were 5, 3, and 4 percent. ^192^ Four deaths were reported during one trial; ^190^ one death resulted from suicide (10 mg group), while the other three (in the 20 mg group) occurred after myocardial infarction, coronary angioplasty, and ischemic cardiomyopathy. None of the deaths was attributed to the effects of vardenafil.

Efficacy. In three trials, ^189,^ ^192,^ ^194^ at 12 weeks after randomization, a dose-related effect of vardenafil with respect to the mean IIEF “EF” domain score was observed. Specifically, patients in either 10 mg or 20 mg vardenafil groups had statistically significant higher mean IIEF “EF” domain scores compared with those in the 5 mg vardenafil groups. Although for five trials ^189,^ ^190,^ ^192,^ ^194,^ ^198^ the differences in the mean IIEF “EF” domain scores observed between the 10 mg and 20 mg were not statistically significant, patients receiving 20 mg of vardenafil had numerically greater scores than those receiving 10 mg vardenafil.

In two trials, ^181,^ ^205^ patients treated with 20 mg had statistically significantly higher mean IIEF “EF” domain scores compared with those treated with 10 mg vardenafil: 19.0 versus 17.1 ^181^ and 22.9 versus 21.8. ^205^ In another trial, ^183^ the mean IIEF “EF” domain score was similar for patients receiving 10 mg and 20 mg of vardenafil (7.7 versus 7.2, respectively).

After 12 weeks of treatment, there was a numerical increase (a statistically nonsignificant improvement) in the mean scores of IIEF-Q3/Q4 ^189,^ ^194^ and SEP-Q2/Q3 ^181,^ ^190,^ ^192^ across the three doses of vardenafil (5 mg versus 10 mg versus 20 mg), the highest being observed in the 20 mg group. For the mean SEP-Q2/Q3, one trial ^205^ demonstrated a statistically significant difference between the two doses of vardenafil (10 mg and 20 mg) in favor of the 20 mg dose.

In one trial, ^194^ the proportion of participants with improved erections (i.e., who answered “yes” to GAQ-Q1) was shown to be statistically significantly greater in the 20 mg versus 5 mg (80 versus 66 percent, p <0.01). Results from two other trials ^189,^ ^192^ demonstrated trends of a numerical increase in the rate of improved erections across 5 mg, 10 mg, and 20 mg doses of vardenafil. The highest proportion of patients with improved erections was observed in the 20 mg groups (range 80.7–86.4 percent). ^189,^ ^192^ In another trial, ^181^ the proportion of participants with improved erections was higher in participants who received 20 mg compared with those who received 10 mg of vardenafil (72 versus 57 percent, p < 0.03).

In one trial, ^193^ the difference in the mean change of the duration of penile rigidity (>60 percent) between the 20 mg and 40 mg doses of vardenafil was not statistically significant (42.9 versus 49.3).

### Quantitative Synthesis - Meta-Analysis of Trials

Series of meta-analyses were performed using efficacy and harms data obtained from the reports of 21 trials ^180^ – ^184,^ ^189,^ ^191^ – ^201,^ ^203^ – ^206^ that were conducted in:

1) Clinically heterogenous groups of patients
2) Clinically homogenous groups of patients

Clinically heterogenous groups of patients - vardenafil (any dose: 5 mg, 10 mg, 20 mg, 40 mg) versus placebo. The analyses presented in this section did not include 10 trials for the following reasons: distinct clinical groups of patients (e.g. those with diabetes, prostatectomy, renal transplant, depression, hypertension); ^181,^ ^183,^ ^196,^ ^199,^ ^204^ – ^206^ crossover design in which no pre-crossover data were reported); ^193,^ ^195^ and lack of measurement or reporting of relevant clinical outcomes. ^180,^ ^195^ Thus, there remained 11 trials that were potentially eligible for meta-analysis. ^182,^ ^184,^ ^189,^ ^191,^ ^192,^ ^194,^ ^197,^ ^198,^ ^200,^ ^201,^ ^203^

Efficacy. Mean IIEF “EF” domain score.

This meta-analysis incorporated three trials ^182,^ ^194,^ ^200^ in which the pooled estimate of mean difference at 12 weeks after randomization was 7.35 (95 percent CI: 6.43–8.27), indicating a statistically significant improvement in the mean IIEF “EF” domain score in participants on vardenafil (any dose) compared with those on placebo. (Figure 38)

Figure 38 The mean IIEF “EF domain” score

Mean per-patient proportion of successful intercourse attempts (SEP-Q2). This meta-analysis was based on two trials of flexible vardenafil dose. ^184,^ ^200^ The estimated mean difference between vardenafil- and placebo-treated participants after 12 weeks of treatment was statistically significant in favor of vardenafil (WMD = 27.59, 95 percent CI: 17.06–38.11). One of the trials ^184^ was restricted to patients who were nonresponders to previous treatment with sildenafil. This difference between the populations of the two trials might have led to the high degree of statistical heterogeneity that was found (I^2^ = 61 percent) (Figure 39).

Figure 39 Successful intercourse attempts (SEP-Q2)

Mean per-patient proportion of successful intercourse attempts (SEP-Q3). This meta-analysis was based on two trials ^184,^ ^200^ and yielded a statistically significant pooled estimate of mean difference for erectile maintenance (SEP-Q3) (WMD = 33.19, 95 percent CI: 26.04–40.33), indicating that the treatment with vardenafil was associated with greater improvements in erectile maintenance frequency compared with placebo. (Figure 40)

Figure 40 Successful intercourse attempts (SEP-Q3)

Proportion of patients with improved erection (GAQ-Q1). Two separate meta-analyses were performed (Figures 41–42). The first incorporated results of 9 trials (Figure 41). ^182,^ ^184,^ ^189,^ ^191,^ ^192,^ ^194,^ ^200,^ ^201,^ ^203^ There was a statistically significantly higher rate of improvement at week 12 in erection among participants who received vardenafil compared with those who received placebo (RR = 2.50, 95 percent CI: 2.19–2.86). The trial that included only participants who did not respond to sildenafil ^184^ had an outlying value of larger effect estimate size (RR = 4.1), leading to a high degree of statistical heterogeneity across the trials (I^2^ = 51.5). The second meta-analysis, which did not incorporate the trial of sildenafil nonresponders ^184^ (see Figure 42), yielded a substantially lower degree of heterogeneity (I^2^ = 3.7) and a pooled RR of 2.38 (95 percent CI: 2.16–2.61). The vardenafil effect size may have been modified by the previous response to sildenafil; specifically, this effect might be greater in sildenafil nonresponders compared with responders or participants naïve to sildenafil or other PDE-5 treatments.

Figure 41 Improved erection (GAQ-Q1)

Figure 42 Improved erection without Carson 2004 (GAQ-Q1)

Proportion of patients with IIEF-EF ≥ 26. This outcome was reported for three trials. ^184,^ ^201,^ ^203^ The pooled estimate of relative risk in the meta-analysis based on the results of these three trials indicated that a higher proportion of participants reached at least 26 on the IIEF score in the vardenafil group compared with the placebo group (RR = 4.05, 95 percent CI: 2.74–6.01) (Figure 43).

Figure 43 IIEF-EF ≥ 26 at follow up (weeks 10–12)

Harms. Proportion of patients with any adverse events (all-cause). The result of this meta-analysis, based on six trials, ^182,^ ^184,^ ^189,^ ^191,^ ^200,^ ^203^ showed a statistically significantly higher incidence of adverse events from any cause among participants who received vardenafil compared with those who received placebo (RR = 1.61, 95 percent CI: 1.40–1.87) (Figure 44). (Note: “favors” in forest plots refers to increased frequency of the event for the respective treatment arm, regardless of desirability of the event)

Figure 44 Any adverse events (all cause)

Patients who withdrew due to adverse events. This meta-analysis incorporated data from 10 trials. ^182,^ ^184,^ ^189,^ ^191,^ ^192,^ ^194,^ ^197,^ ^198,^ ^201,^ ^203^ Although the pooled effect estimate of RR indicated a 29 percent increase in the rate of withdrawal due to adverse events for patients treated with vardenafil relative to those treated with placebo, the observed difference in rates between the two treatment groups was not statistically significant (RR = 1.29, 95 percent CI: 0.78–2.13) (Figure 45).

Figure 45 Withdrawals due to adverse events

Patients with serious adverse events (all-cause). This meta-analysis incorporated 9 trials. ^182,^ ^184,^ ^191,^ ^192,^ ^197,^ ^198,^ ^200,^ ^201,^ ^203^ Although the pooled effect estimate of RR indicated a 34 percent increase in the risk of experiencing at least one serious adverse event among patients treated with vardenafil relative to those treated with placebo, the observed difference in the rates between the two treatment groups was not statistically significant (RR = 1.34, 95 percent CI: 0.76–2.36) (Figure 46).

Figure 46 Serious adverse events

Patients with headache (all-cause). This meta-analysis incorporated the results of nine trials. ^182,^ ^191,^ ^192,^ ^194,^ ^197,^ ^198,^ ^200,^ ^203,^ ^213^ According to the pooled estimate, the use of vardenafil was associated with a significantly increased risk of headache relative to the use of placebo (RR = 4.10, 95 percent CI: 2.56–6.57) (Figure 47).

Figure 47 Headache (all cause)

Proportion of patients with flushing (all-cause). This meta-analysis included nine trials. ^182,^ ^191,^ ^192,^ ^194,^ ^197,^ ^198,^ ^200,^ ^201,^ ^203^ Patients treated with vardenafil patients were at a statistically significant increased risk of flushing compared with patients treated with placebo (RR = 10.22, 95 percent CI: 5.26–19.87). The magnitude of the pooled RR may have been an overestimate of the true RR because low counts observed in the placebo arms which would cause some instability and inflation of individual estimates of RR (Figure 48).

Figure 48 Flushing (all cause)

Proportion of patients with dyspepsia (all-cause). This meta-analysis included six trials, ^182,^ ^191,^ ^192,^ ^194,^ ^197,^ ^198^ the outcome of dyspepsia was not ascertainable for five trials. ^184,^ ^189,^ ^200,^ ^201,^ ^203^ Patients who received vardenafil were at a statistically significantly higher risk of dyspepsia compared with those who received placebo (RR = 6.58, 95 percent CI: 2.61–16.60) (Figure 49).

Figure 49 Dyspepsia (all cause)

Clinically homogenous groups of patients. Seven trials included ED patients who additionally presented with diabetes Types I and II, ^181,^ ^204,^ ^205^ nerve-sparing retropubic prostatectomy, ^183^ renal transplantation, ^206^ untreated mild major depression, ^199^ or arterial hypertension. ^196^ Only three trials ^181,^ ^204,^ ^205^ including diabetic patients were potentially suitable for meta-analysis.

Efficacy. Meta-analyses for efficacy outcomes in diabetes patients were not performed in view of missing qualitative or quantitative information (i.e., the outcome was not reported at all or no numerical data were given on measures of variability).

Harms. Patients with serious adverse events (all-cause). This meta-analysis included results from three trials. ^181,^ ^204,^ ^205^ There was a statistically nonsignificant finding of a 40 percent increased risk of a serious adverse event in patients who received vardenafil versus those who received placebo (RR = 1.40, 95 percent CI: 0.59–3.29) (Figure 50).

Figure 50 Serious adverse events: patients with diabetes

Patients who withdrew due to adverse events. This meta-analysis included results from three trials of patients with diabetes. ^181,^ ^204,^ ^205^ The difference in the withdrawal rates resulting from adverse events between these patients in vardenafil and placebo groups was not statistically significant (RR = 1.80, 95 percent CI: 0.66–4.91) (Figure 51).

Figure 51 Withdrawals due to adverse events: patients with diabetes

Dose-response effect of vardenafil (20 mg versus 10 mg). There were 10 trials with two or more dose-specific arms of vardenafil. ^181,^ ^183,^ ^189,^ ^190,^ ^192^ – ^195,^ ^198,^ ^205^ The analysis in this section excluded trials of distinct clinical groups of patients ^181,^ ^183,^ ^205^ and crossover trials. ^193,^ ^195^ Therefore, five potentially eligible trials remained for the analyses. ^189,^ ^190,^ ^192,^ ^194,^ ^198^ Meta-analysis could be performed with respect to only one efficacy outcome, the IIEF “EF” domain endpoint score. For other efficacy outcomes (IIEF-Q3/Q4, SEP-Q2/Q3) quantitative data necessary for meta-analysis were missing. ^189,^ ^190,^ ^192,^ ^198^

Efficacy. Mean IIEF “EF” domain score. This meta-analysis incorporated two trials. ^190,^ ^194^ The estimate of pooled mean difference for the IIEF “EF” domain score observed between the two groups of patients at weeks 12–104 was not statistically significant (WMD = 0.92, 95 percent CI: -0.03 to 1.87) (Figure 52).

Figure 52 The mean IIEF “EF domain” score (at week 12–104)

Proportion of patients with improved erection (GAQ-Q1). This meta-analysis incorporated results of four trials. ^189,^ ^190,^ ^192,^ ^194^ The proportion of patients with improved erection at week 12 was similar in the 20 mg and 10 mg vardenafil treatment groups (RR = 1.03, 95 percent CI: 0.99–1.08) (Figure 53).

Figure 53 Improved erection (GAQ-Q1) (at week 12)

Harms. Proportion of patients with any adverse events (all cause). The result of this meta-analysis, incorporating two trials, ^189,^ ^190^ indicated a marginally statistically significant increase in risk for any adverse event for patients treated with 20 mg vardenafil compared with those treated with 10 mg vardenafil (RR = 1.15, 95 percent CI: 1.06–1.25) (Figure 54).

Figure 54 Any adverse events (all cause)

Proportion of patients with serious adverse events (all cause). This meta-analysis was based on results of three trials. ^190,^ ^192,^ ^198^ The occurrence of serious adverse events could not be ascertained for two trials. ^189,^ ^194^ The pooled estimate of relative risk indicated that the risk of developing any serious adverse event did not differ between the groups of patients receiving 20 mg and 10 mg doses of vardenafil (RR = 1.02, 95 percent CI: 0.37–2.82) (Figure 55).

Figure 55 Serious adverse events (all cause)

Patients who withdrew due to adverse events. This meta-analysis included five trials. ^189,^ ^190,^ ^192,^ ^194,^ ^198^ The difference in withdrawal rates resulting from adverse events observed between patients treated with 20 mg and 10 mg doses of vardenafil was not statistically significant (RR = 1.60, 95 percent CI: 0.85–3.00) (Figure 56).

Figure 56 Withdrawals due to adverse events

Patients with headache, flushing, or dyspepsia (all cause). Three meta-analyses, each incorporating results from three trials, ^192,^ ^194,^ ^198^ were performed separately for the incidence of headache, flushing, and dyspepsia (Figures 57–59). The occurrence of these events could not be ascertained for two trials. ^189,^ ^190^

Figure 58 Flushing (all cause)

Figure 57 Headache (all cause)

Figure 59 Dyspepsia (all cause)

Although the pooled effect estimates indicated an increased risk ranging from 25 percent (RR = 1.25, 95 percent CI: 0.87–1.79) to 56 percent (RR = 1.56, 95 percent CI: 0.83–2.91) for the occurrence of any of these events in patients treated with 20 mg vardenafil versus 10 mg vardenafil, none of these estimates reached statistical significance.

### Assessment of Publication Bias

Funnel plots were generated and examined to graphically assess the extent of asymmetry (i.e., possible publication bias) present in each meta-analysis. Visual inspection of these plots did not reveal any substantial asymmetry. ^53^ (Figures D-9–11, Appendix D)

## Oral Treatments — Phosphodiesterase Type 5 (PDE-5) Inhibitors - Tadalafil

### Literature Search

In total, 30 RCTs (in 37 publications) met the eligibility criteria and were included in the review. ^103,^ ^118,^ ^121,^ ^163,^ ^214^ – ^247^

One additional trial, ^231^ which employed the combination of topical testosterone and tadalafil is described in the section on hormonal treatments.

Results of four unique trials were presented in multiple publications. The following list shows the reference identifications for these trials and corresponding publications (each row).

The first reference (author, year, citation) denotes primary publications (i.e., those reporting the most relevant and complete data for the trial), which are used throughout the Tadalafil section. (Table F-3, Appendix F)

1 Eardley 2005 ^103^ and Dean 2006 ^241^
2 Mirone 2005, ^214^ Moncada 2005, ^244^ Costa 2006, ^245^ Wespes 2007, ^246^ Buvat 2006 ^247^
3 McMahon 2005 ^216^ and McMahon 2006 ^242^
4 Carson 2005 ^217^ and Carson 2005 ^243^

### Overview of Trials

The trials were conducted in the US, ^118,^ ^121,^ ^215,^ ^217,^ ^222,^ ^224,^ ^225,^ ^230,^ ^233,^ ^235^ Canada, ^221,^ ^222,^ ^227^ Europe/UK, ^103,^ ^118,^ ^121,^ ^163,^ ^214,^ ^218^ – ^220,^ ^222,^ ^223,^ ^225,^ ^226,^ ^232,^ ^234,^ ^239^ East and Southeast Asia, ^229,^ ^236,^ ^237,^ ^240^ Japan, ^238^ and Australia. ^216,^ ^228,^ ^242^ The trials were published between 2002 ^226^ and 2007 ^232,^ ^233,^ ^235^ inclusively. The authors of all trials but three ^163,^ ^218,^ ^219^ stated that the trials were funded by Lilly ICOS LLC. Of the two Italian trials, ^218,^ ^219^ one was funded by Pfizer; ^218^ the other ^219^ did not report the funding source.

Of the 30 trials, 22 were parallel-arm ^215^ – ^227,^ ^229,^ ^230,^ ^233^ – ^238,^ ^240^ and eight were ^103,^ ^118,^ ^121,^ ^163,^ ^214,^ ^228,^ ^232,^ ^239^ crossover trials. Of the 22 parallel-arm trials, 13 had two arms ^216^ – ^220,^ ^222^ – ^225,^ ^233,^ ^234,^ ^236,^ ^240^ and nine trials had three or more arms. ^215,^ ^221,^ ^226,^ ^227,^ ^229,^ ^230,^ ^235,^ ^237,^ ^238^ Of the 30 trials, 23 were placebo controlled ^215^ – ^227,^ ^229,^ ^230,^ ^233^ – ^240^ and seven were active-arm (e.g. sildenafil, tadalafil, vardenafil) controlled trials. ^103,^ ^118,^ ^121,^ ^163,^ ^214,^ ^228,^ ^232^ Further information on trial characteristics is provided in Table F-3 (Appendix F).

### Populations

The included trials involved men diagnosed with ED. The total and mean numbers of patients randomly assigned to study interventions or placebo across the 30 trials were 10,718 and 358, respectively. The number of patients randomly assigned across the trials ranged from 20 ^232^ to 4,262. ^214^

The inclusion criteria in all trials except five ^218,^ ^222,^ ^226,^ ^233,^ ^239^ were: adult males aged ≥18 years, diagnosed with ED for ≥3 months, and in a stable monogamous heterosexual relationship. The inclusion criteria in two studies ^222,^ ^226^ were restricted to patients who either additionally had diabetes (Type I or II) ^226^ or who had undergone bilateral nerve-sparing retropubic prostatectomy 1–4 years before their enrolment into the trial. ^222^ In one trial, ^218^ the study population consisted of mostly older men, aged 59–71 years, who had two or more risk factors for coronary artery disease (CAD) (e.g. total cholesterol level >5.20 mmol/L, diabetes Type II, hypertension >135/85 mmHg, tobacco smoking, family history). Only 50 percent of these patients had ED. In two other trials ^233,^ ^239^ the patient populations comprised those with lower urinary tract symptoms (LUTS) secondary to benign prostatic hyperplasia (BPH) ^233^ and patients with ED undergoing three-dimensional conformal external-beam radiotherapy (3DCRT) for prostatic carcinoma. ^239^ In the former trial, ^233^ only 65 percent (183,281) of the patients had ED. In one trial, ^163^ only PDE-5 naïve patients were enrolled.

The exclusion criteria in the majority of included trials were pelvic surgery, ^103,^ ^118,^ ^121,^ ^215,^ ^216,^ ^219^ – ^223,^ ^225,^ ^229,^ ^233,^ ^235^ – ^240^ penile/testicular deformity, ^103,^ ^215,^ ^216,^ ^219,^ ^221^ – ^225,^ ^227,^ ^228,^ ^230,^ ^234^ – ^236,^ ^238^ unstable angina/myocardial infarction, ^103,^ ^118,^ ^121,^ ^163,^ ^215^ – ^218,^ ^220^ – ^222,^ ^224,^ ^225,^ ^227^ – ^229,^ ^232^ – ^240^ prostatectomy, ^103,^ ^216,^ ^217,^ ^220,^ ^221,^ ^223^ – ^225,^ ^227^ – ^230,^ ^233^ – ^238,^ ^240^ HIV-positivity/AIDS, ^103,^ ^118,^ ^121,^ ^221^ – ^223,^ ^227,^ ^229,^ ^230,^ ^235^ – ^238,^ ^240^ use of nitrates, ^103,^ ^118,^ ^121,^ ^163,^ ^214,^ ^215,^ ^217,^ ^219,^ ^220,^ ^222,^ ^227,^ ^229,^ ^230,^ ^232^ – ^235,^ ^237^ – ^240^ any major hepatic/renal disease, ^103,^ ^216,^ ^219^ – ^224,^ ^227,^ ^228,^ ^233,^ ^234,^ ^236^ – ^238,^ ^240^ previous ineffective treatment with sildenafil, ^216,^ ^217,^ ^221,^ ^223,^ ^224,^ ^227,^ ^229,^ ^230,^ ^234,^ ^235,^ ^238^ stroke, ^103,^ ^118,^ ^121,^ ^214,^ ^215,^ ^217,^ ^219,^ ^224,^ ^225,^ ^228,^ ^233^ – ^235,^ ^238,^ ^239^ endocrine disease, ^103,^ ^118,^ ^216,^ ^221,^ ^223,^ ^230,^ ^234^ – ^236,^ ^238^ retinitis pigmentosa, ^103,^ ^118,^ ^121,^ ^163,^ ^228^ or a history of cancer. ^214,^ ^215,^ ^219,^ ^227,^ ^229,^ ^230,^ ^233,^ ^239,^ ^240^ Other exclusion criteria were cancer chemotherapy ^232^ – ^235,^ ^237^ – ^240^ premature ejaculation, ^234^ – ^236,^ ^238^ spinal cord injury ^215,^ ^219,^ ^233^ – ^235,^ ^239^ uncontrolled hypertension, ^103,^ ^217,^ ^233,^ ^235,^ ^236,^ ^238^ use of alpha-blockers/androgens, ^163,^ ^238^ and diabetes. ^216,^ ^221^ – ^223,^ ^233,^ ^234,^ ^236^ One trial additionally excluded patients with prostate-specific antigen levels >10 ng/mL. ^233^ None of the trials failed to report exclusion criteria.

The mean age of the study participants across the included trials ranged from 46 ^219^ to 69 ^239^ years. The patients' race was not reported in eight trials. ^217^ – ^219,^ ^223,^ ^228,^ ^229,^ ^232,^ ^239^ Three trials included Southeast Asian, ^236,^ ^237,^ ^240^ one trial Japanese, ^238^ and one trial Turkish and Egyptian patients. ^234^ The approximate proportion of Caucasians in the remaining 17 trials ranged from 73 percent ^224^ to 100 percent. ^163,^ ^220^ The duration of ED of patients was not reported in four trials. ^218,^ ^219,^ ^221,^ ^222^ In 24 of the remaining 26 trials, ^103,^ ^118,^ ^121,^ ^214^ – ^217,^ ^220,^ ^223^ – ^230,^ ^232^ – ^238,^ ^240^ eligible patients had to have been diagnosed with ED for at least 3 months before their enrolment into the trial. In two trials, patients had been diagnosed with ED for at least 6 ^163^ and 12 months ^239^ before trial enrolment. In 22 trials, the majority of patients (≥70 percent) had been diagnosed with ED for at least 1 year before trial entry. ^103,^ ^118,^ ^121,^ ^214^ – ^217,^ ^220,^ ^223^ – ^227,^ ^229,^ ^230,^ ^234^ – ^240^

The most commonly reported comorbidities among study participants were diabetes, ^103,^ ^118,^ ^163,^ ^214^ – ^217,^ ^220,^ ^221,^ ^223,^ ^224,^ ^226^ – ^230,^ ^232,^ ^234^ – ^238,^ ^240^ hypertension, ^103,^ ^118,^ ^163,^ ^214^ – ^217,^ ^220,^ ^223,^ ^224,^ ^226^ – ^230,^ ^232,^ ^234^ – ^240^ coronary artery disease (CAD), ^103,^ ^118,^ ^163,^ ^214,^ ^215,^ ^217,^ ^221,^ ^224,^ ^228,^ ^229,^ ^235^ hyperlipidemia, ^163,^ ^214,^ ^216,^ ^217,^ ^223,^ ^224,^ ^226,^ ^227,^ ^229,^ ^230,^ ^232,^ ^234,^ ^235,^ ^237,^ ^238,^ ^240^ BPH, ^223,^ ^224,^ ^233,^ ^234,^ ^236^ – ^238,^ ^240^ and depression. ^103,^ ^118,^ ^214,^ ^224,^ ^230,^ ^235^ The presence or absence of comorbidities could not be ascertained for six trials. ^121,^ ^218,^ ^219,^ ^222,^ ^225,^ ^233^ In three trials, ^103,^ ^215,^ ^239^ the proportion of ED patients with diabetes was below 10 percent; in five trials, ^216,^ ^220,^ ^223,^ ^235,^ ^237^ this proportion ranged from 11 percent ^220^ to 14 percent; ^235^ in four trials ^118,^ ^214,^ ^224,^ ^240^ it ranged from 17 percent ^118,^ ^224^ to 18 percent; ^214,^ ^244^ – ^247^ and in 10 trials ^217,^ ^221,^ ^227^ – ^230,^ ^232,^ ^234,^ ^236,^ ^238^ the proportion ranged from 20 percent ^217,^ ^227,^ ^232^ to 31 percent. ^236^ In two trials ^234,^ ^240^ the proportion of ED patients with hypertension ranged from 14 percent ^240^ to 17 percent. ^234^ In other 12 trials ^103,^ ^118,^ ^214,^ ^218,^ ^220,^ ^227^ – ^229,^ ^232,^ ^237^ – ^239^ this proportion ranged from 20 percent ^232^ to 29 percent, ^228^ and in eight trials ^215^ – ^217,^ ^223,^ ^224,^ ^230,^ ^235,^ ^236^ from 30 percent ^216,^ ^236^ to 43 percent. ^235^ The remaining eight trials ^121,^ ^163,^ ^219,^ ^221,^ ^222,^ ^225,^ ^226,^ ^233^ failed to report the proportion of hypertensive patients. The proportion of ED patients with CAD in six trials ^103,^ ^118,^ ^214,^ ^215,^ ^224,^ ^229,^ ^241^ was below 10 percent, and in three trials ^217,^ ^228,^ ^235^ it ranged around 10–11 percent. The proportion of patients with CAD could not be ascertained from the remaining 21 trials.

The approximate proportion of smokers was ascertained for 17 trials, ^103,^ ^118,^ ^121,^ ^214,^ ^215,^ ^217^ – ^221,^ ^225,^ ^227^ – ^229,^ ^232,^ ^234,^ ^238^ and ranged from 15–16 percent ^215,^ ^217^ to 37–40 percent. ^229,^ ^238^ The authors of 13 trials ^163,^ ^216,^ ^222^ – ^224,^ ^226,^ ^230,^ ^233,^ ^235^ – ^237,^ ^239,^ ^240^ did not report the proportion of smokers.

The majority of the trials included patients with ED of all three etiologic groups (i.e., organic, psychogenic, and mixed. ^103,^ ^118,^ ^121,^ ^163,^ ^214^ – ^217,^ ^219,^ ^220,^ ^223^ – ^225,^ ^227^ – ^229,^ ^232,^ ^234^ – ^238,^ ^240^ In eight trials ^118,^ ^215^ – ^217,^ ^227,^ ^229,^ ^234,^ ^235^ the proportion of patients with ED of psychogenic origin was below 10 percent, whereas in 13 other trials ^103,^ ^121,^ ^214,^ ^219,^ ^220,^ ^223^ – ^225,^ ^228,^ ^236^ – ^238,^ ^240^ this proportion ranged from about 10 percent ^224^ to 29 percent. ^238^

The approximate proportion of patients with severe ED (IIEF “EF” domain score: 1–10) across 24 trials ^103,^ ^118,^ ^121,^ ^214^ – ^217,^ ^219^ – ^225,^ ^227^ – ^230,^ ^234^ – ^238,^ ^240^ ranged from 18–23 percent ^223,^ ^228,^ ^240^ to 50–52 percent. ^217,^ ^222^ In 14 trials, ^103,^ ^214^ – ^216,^ ^219^ – ^221,^ ^224,^ ^225,^ ^227,^ ^230,^ ^235,^ ^237,^ ^238^ the approximate proportion of patients with severe ED ranged from 30–32 percent ^103,^ ^237,^ ^241^ to 40–42 percent. ^220,^ ^224,^ ^235^ In seven trials, ^118,^ ^121,^ ^223,^ ^228,^ ^229,^ ^234,^ ^236^ this proportion was from 20 to 30 percent. The proportion of patients by ED severity groups was not reported in six trials. ^163,^ ^218,^ ^226,^ ^232,^ ^233,^ ^239^

### Interventions

Patients across the 30 trials that were reviewed received oral tadalafil monotherapy in either experimental or active control arms. In most of the trials, tadalafil was given in 10 mg ^215,^ ^221,^ ^226^ – ^230,^ ^237,^ ^238^ and 20 mg doses. ^118,^ ^121,^ ^163,^ ^214^ – ^220,^ ^222^ – ^230,^ ^232,^ ^234,^ ^236^ – ^240^ One trial ^221^ included three additional randomized arms in which patients received 2 mg, 5 mg or 25 mg of tadalafil. In another trial, ^238^ one additional arm of randomly assigned patients received 5 mg of tadalafil. In one placebo-controlled trial, ^235^ patients were randomly assigned to receive either 2.5 mg or 5 mg of tadalafil. Dose escalations were used in two trials: 10–20 mg ^103^ and 5–20 mg. ^233^

In three trials, ^214,^ ^228,^ ^232^ 20 mg tadalafil on demand was compared with 20 mg three times per week, ^214^ 20 mg on alternate days, ^232^ or 10 mg daily. ^228^ In addition to these three trials, ^214,^ ^228,^ ^232^ a fixed dose of tadalafil was used in nine others. ^118,^ ^121,^ ^163,^ ^217^ – ^220,^ ^225,^ ^235^ “On demand” (i.e., “as needed”) dosing of tadalafil was used in 17 trials. ^103,^ ^215,^ ^216,^ ^221^ – ^224,^ ^226,^ ^229,^ ^230,^ ^234,^ ^236^ – ^240^

The duration of tadalafil treatment across the trials ranged from about 4–6 weeks ^214,^ ^215,^ ^218,^ ^230,^ ^232,^ ^233,^ ^239^ to 24–26 weeks. ^216^ In half of the trials, tadalafil was administered for about 12 weeks. ^103,^ ^118,^ ^217,^ ^219,^ ^220,^ ^222^ – ^224,^ ^226^ – ^229,^ ^234,^ ^236^ – ^238^

Tadalafil was compared with placebo, ^215^ – ^227,^ ^229,^ ^230,^ ^233^ – ^240^ , sildenafil ^103,^ ^118,^ ^121,^ ^163^ , tadalafil (control dose/dosing regimen), ^214,^ ^215,^ ^221,^ ^226^ – ^230,^ ^232,^ ^235,^ ^237,^ ^238^ , and vardenafil. ^163^

### Outcomes

In total, all 30 trials reported some information on the absence and/or occurrence of either total or serious adverse events. In four trials, the incidence of any adverse events was not reported. ^121,^ ^217,^ ^221,^ ^224,^ ^232^ Authors of 14 trials failed to report the absence or occurrence of serious adverse events. ^118,^ ^121,^ ^163,^ ^216,^ ^218,^ ^219,^ ^221,^ ^225^ – ^227,^ ^229,^ ^230,^ ^232,^ ^237^ The number of patients who withdrew as a result of adverse events was reported in all but two trials. ^221,^ ^232^

Efficacy. The efficacy outcomes measured in the 30 included trials varied to some degree. The most commonly measured and reported outcomes across the trials were the mean or median endpoint score/mean score change on IIEF domains and/or individual questions, ^103,^ ^163,^ ^214,^ ^216,^ ^217,^ ^219,^ ^220,^ ^222^ – ^224,^ ^226^ – ^229,^ ^233,^ ^234,^ ^236^ – ^240,^ ^242,^ ^243^ the mean endpoint/ mean change in the per-patient proportion of “yes” answers to the Sexual Encounter Profile questions 2 and 3 (i.e., SEP-2/3, “Were you able to insert your penis into your partner's vagina?” and “Did your erection last long enough for you to have successful intercourse?”), ^103,^ ^214^ – ^217,^ ^219,^ ^220,^ ^222^ – ^230,^ ^234,^ ^236^ – ^240,^ ^243^ and the proportion of patients who answered “yes” to the Global Assessment Question 1 or 2 (i.e. GAQ-Q1: “Has the treatment you have been taking improved your erections?” and GAQ-Q2: “If yes, has the treatment improved your ability to engage in sexual activity?”). ^216,^ ^217,^ ^220,^ ^222^ – ^224,^ ^226^ – ^229,^ ^234,^ ^236^ – ^240^ Of the 16 trials that reported outcomes based on GAQs, nine trials ^216,^ ^217,^ ^224,^ ^226^ – ^229,^ ^237^ ^238^ evaluated the proportion of patients who answered “yes” to GAQ-Q1 only, whereas the remaining seven trials ^220,^ ^222,^ ^223,^ ^234,^ ^236,^ ^239,^ ^240,^ evaluated this parameter for both GAQ-Q1 and GAQ-Q2.

Eight trials additionally evaluated the efficacy (i.e., the mean per-patient percentage of successful intercourse attempts based on “yes” responses to SEP Q3) for different time-periods after dosing of tadalafil. ^216,^ ^217,^ ^219,^ ^220,^ ^224,^ ^225,^ ^227,^ ^230^

The authors of one trial, ^221^ derived logistic regression models based on the patient data obtained from a randomized placebo-controlled trial. These dose-response models assessed the relationship between the dose of tadalafil (2, 5, 10, or 25 mg) and the probability of getting an outcome (SEP questions 2 and 3 and/or on IIEF questions 3 and 4). The models included such covariates as baseline severity of ED and IIEF-EF domain score.

In five trials, ^103,^ ^163,^ ^217,^ ^222,^ ^223,^ ^241,^ ^243^ treatment satisfaction was measured using the Erectile Dysfunction Inventory of Treatment Satisfaction (EDITS) questionnaire.

The patients' treatment preference (e.g. percentage of patients who preferred the use of tadalafil to that of sildenafil) was evaluated and reported in six trials, all of which were of a crossover design in which the patients received both tadalafil and sildenafil ^103,^ ^118,^ ^121,^ ^163,^ ^241^ or alternating dosing regimens of tadalafil (i.e., on demand versus fixed). ^214,^ ^228,^ ^244^ – ^247^

Endothelial function using percentage change (compared with baseline) in the mean flow mediated dilation (FMD) of brachial and cavernous arteries was measured in two trials. ^218,^ ^232^

### Study Quality and Reporting

The mean Jadad total score for the 30 included trials was 3.2. The individual Jadad total score for 30 trials ranged from 1 ^163^ to 5. ^216,^ ^222,^ ^225^ All 30 trials but six ^103,^ ^163,^ ^214,^ ^219,^ ^228,^ ^232^ were double-blind. Three trials could not have been double blinded because patients received either on-demand or fixed dosing regimens of tadalafil. ^214,^ ^228,^ ^232^ Of the 24 double-blind trials, only nine trials ^118,^ ^216,^ ^218,^ ^221,^ ^222,^ ^224,^ ^225,^ ^227,^ ^239^ reported some description of the blinding method(s) used. Only three trials ^219,^ ^238,^ ^239^ reported some information on the allocation concealment, which was deemed to be adequate. The adequacy of allocation concealment for the remaining 27 trials could not be ascertained (i.e., was unclear).

Of the eight crossover trials, ^103,^ ^118,^ ^121,^ ^163,^ ^214,^ ^228,^ ^232,^ ^239^ only one ^239^ failed to report whether a washout period had been applied between the treatment periods. The length of washout period for the seven remaining crossover trials ranged from 4 days ^118^ to 14 days. ^121,^ ^228,^ ^232^

### Qualitative Synthesis

Tadalafil (any dose: fixed or flexible) versus placebo.

Harms. The occurrence of total and serious adverse events across the 23 placebo-controlled trials was reported poorly. ^215^ – ^227,^ ^229,^ ^230,^ ^233^ – ^240^

In the majority of these trials, the frequency of any adverse events (i.e., the proportion of patients with at least one adverse event) was greater either numerically or with statistical significance in the tadalafil arms than in the placebo arms. ^215,^ ^220,^ ^222,^ ^223,^ ^225^ – ^227,^ ^229,^ ^230,^ ^236^ – ^240^

For example, in one trial, the proportion of patients who experienced at least one adverse event in the tadalafil and placebo arms were 51.7 versus 26.5 percent, respectively (p < 0.001). ^222^ In another trial, ^225^ the corresponding numbers were 40 (22.5 percent) versus two (1.3 percent) (p value was not reported). Even though the proportion of patients in one trial ^226^ was numerically greater in the tadalafil arms (39.7–44.4 percent) than in the placebo arm (31.0 percent), this difference was not statistically significant (p = 0.247). Most common adverse events reported across all trials were headache, back pain, dyspepsia, dizziness, nasal congestion, flushing, and myalgia. In general, the occurrence of these events tended to be numerically more frequent in tadalafil arms than in placebo arms. Moreover, a statistically significant higher incidence of these events was reported across several trials in tadalafil versus placebo arms. ^215,^ ^220,^ ^222,^ ^223,^ ^225,^ ^226,^ ^239^ The majority of the trials reported that tadalafil was well tolerated and that patients had had adverse events mostly of mild or moderate severity.

Eleven of the 23 trials did not report whether there had been any occurrence of serious adverse events. ^216,^ ^218,^ ^219,^ ^221,^ ^225^ – ^227,^ ^229,^ ^230,^ ^237,^ ^239^

In the remaining 12 trials, ^215,^ ^217,^ ^220,^ ^222^ – ^224,^ ^233^ – ^236,^ ^238,^ ^240^ the incidence of serious adverse events (i.e., the proportion of patients with at least one serious adverse event) was reported to have been about 5.0 percent ^222^ or less, or 0, ^238^ , and to have been similar in tadalafil and placebo arms. ^215,^ ^217,^ ^220,^ ^222^ – ^224,^ ^233,^ ^235,^ ^240^ In one trial, ^217,^ ^243^ three patients who received tadalafil developed carotid artery bruit, esophageal spasm, and brain neoplasm (one case of each event). ^217^ Other specific serious adverse events that were reported were single cases of pulmonary embolism and subarachnoid hemorrhage, ^223^ two cases of chest pain requiring hospital admission, ^224^ and one case of worsening CAD. ^236^ In one trial, ^235^ five patients experienced at least one of the following serious adverse events in the tadalafil arm: acute myocardial infarction (AMI), benign lung neoplasm, back pain, road traffic accident, and pancreatitis. Two trials ^215,^ ^234^ reported one death each which had occurred due to AMI ^215^ and cardiac arrest. ^234^ Of the 12 trials that reported any occurrence of serious adverse events, three trials ^215,^ ^220,^ ^222^ did not specify what these events were.

The proportion of patients who withdrew due to adverse events across trials was five–six percent ^217,^ ^222,^ ^224^ or less and similar across the tadalafil and placebo arms. ^215^ – ^220,^ ^222^ – ^227,^ ^229,^ ^230,^ ^233^ – ^240^

Efficacy. In general, the results of the 23 placebo-controlled trials showed that patients who received tadalafil (10 or 20 mg) experienced greater improvement in erectile functioning (e.g. outcomes based on responses to IIEF, SEP, and GAQ) compared with those who received placebo. The observed between- or within-arm differences in the mean endpoint scores/mean score changes for the IIEF “EF” domain ^216,^ ^217,^ ^219,^ ^220,^ ^222^ – ^224,^ ^226,^ ^227,^ ^229,^ ^234,^ ^236^ – ^240^ and for the per-patient proportion of “yes” answers to the SEP questions 2–3, were statistically significant (p value < 0.05). ^215^ – ^217,^ ^219,^ ^220,^ ^222^ – ^227,^ ^229,^ ^230,^ ^234,^ ^236^ – ^240^ Similarly, the proportion of patients who answered “yes” to the GAQ-Q1/2 was statistically significantly greater in tadalafil than in placebo arms. ^216,^ ^217,^ ^220,^ ^222^ – ^224,^ ^226,^ ^227,^ ^229,^ ^234,^ ^236^ – ^240^

For example, the mean within-arm IIEF “EF” domain absolute score change observed in tadalafil arms (10 or 20 mg dose) across trials ^216,^ ^217,^ ^219,^ ^220,^ ^222^ – ^224,^ ^226,^ ^227,^ ^229,^ ^234,^ ^236^ – ^240^ ranged from 5.2 ^222^ to 12.0, ^219^ whereas the corresponding treatment response observed in placebo arms ranged from -1.6 ^216,^ ^242^ to 2.9. ^219^ The mean change in the proportion who responded “yes” to SEP Q3 (i.e., per-patient percentage of successful intercourse attempts) in tadalafil arms (10 or 20 mg dose) ranged from 23.0 percent ^222^ to 56.5 percent. ^220,^ ^237^ The corresponding mean treatment response change in placebo arms ranged from 0.9 percent ^216^ to 18.3 percent. ^237^ The proportion of patients who responded “yes” to GAQ-Q1 in tadalafil arms (10 or 20 mg) across trials ^216,^ ^217,^ ^220,^ ^222^ – ^224,^ ^226,^ ^227,^ ^229,^ ^234,^ ^236^ – ^240^ ranged from 62.0 percent ^222^ to 92.3 percent. ^229^ For placebo arms this proportion across the same trials ranged from 12.8 percent ^216^ to 54.5 percent. ^229^

In a parallel-arm trial of patients with LUTS (65 percent ED patients), ^233^ 138 patients (n = 99 ED patients) received the dose-escalated tadalafil (5 mg for 6 weeks and the 5–20 mg dose-escalation for another 6 weeks) and, compared with those receiving placebo, had a statistically significant greater mean change in the IIEF “EF” domain score at 6 and 12 weeks of treatment (12 weeks: 7.7 versus 1.4, p < 0.001). Furthermore, results of two trials ^235,^ ^238^ indicated that patients receiving even lower doses of tadalafil (2.5 mg and 5 mg) compared with those in the placebo group had greater statistically significant improvements in erectile functioning with respect to the mean score changes in the IIEF “EF” domain (19.1–20.8 versus 14.6, p < 0.001) and the per-patient proportion of “yes” answer to SEP Q2–3 (for Q2: 65.3–70.7 versus 51.1, p < 0.001 and for Q3: 50.0–57.0 versus 31.3, p < 0.001). ^235^ Compared with the placebo group, in both tadalafil dose-groups there was a significantly greater proportion of patients who answered “yes” to GAQ1–2 (5 mg: 70.7–72.8 percent, versus 2.5 mg: 58.5–62.8 percent, versus placebo: 23.9–26.1 percent). ^235^

Furthermore, patients who received tadalafil compared with those who received placebo had statistically significant greater improvements in erectile function as measured by the mean IIEF score change from baseline to endpoint for the IIEF “Intercourse Satisfaction” and “Overall Satisfaction” domains. ^216,^ ^217,^ ^223,^ ^224,^ ^226,^ ^227,^ ^229,^ ^234^ – ^240,^ ^243^

In several trials, there was a statistically significant greater mean per-patient percentage of successful intercourse attempts measured at different intervals after dosing in tadalafil arms compared with placebo arms. ^217,^ ^219,^ ^220,^ ^224,^ ^225,^ ^230^

The mean overall EDITS score in patients who received tadalafil showed a statistically significant improvement compared with that in patients who received placebo. ^217,^ ^222,^ ^223^ The mean overall EDITS score values in tadalafil arms across the trials were 66.8, ^217,^ ^243^ 58.0, ^222^ and 77. ^223^ The corresponding values for placebo arms in these trials were 35.6, 34.0, and 46.0, respectively. In one of these trials, ^223^ patients treated with tadalafil had a median EDITS score of 84,(95 percent CI: 80–86) as opposed to those treated with placebo, who had a median EDITS score of 41 (95 percent CI: 32–59). The difference between the two median scores was statistically significant (p <0.001).

The mean change measured on individual IIEF Q3–4 scores (Q3, penetration ability; Q4, maintenance ability) was reported in 8 trials (out of the 23 placebo-controlled trials), ^217,^ ^220,^ ^226,^ ^234^ – ^237,^ ^240^ all of which showed highly statistically significant improvements for patients treated with tadalafil patients compared with those treated with placebo (p < 0.001).

The authors of one trial ^218^ showed that after a 4-week therapy, patients treated with tadalafil experienced greater improvements in endothelial function as measured by brachial artery flow-mediated dilation (FMD) than patients treated with placebo. For example, in the tadalafil arm, the mean change in FMD from baseline to the end point was statistically significant (9.3 versus 4.2 percent, p < 0.01), whereas in the placebo arm the mean FMD did not change (4.1 versus 4.3, p >0.05).

Four studies examined the efficacy according to severity of ED. ^216,^ ^235,^ ^237,^ ^238^ The number of patients achieving normal scores in IIEF-EF were higher in mild ED compared with moderate or severe ED. ^216,^ ^235,^ ^237,^ ^238^ Similarly higher end scores of IIEF-EF were achieved in patients with mild compared with moderate or severe ED. ^216,^ ^235,^ ^237,^ ^238^ (Table 11)

Table 11 Efficacy Results of Tadalafil by ED Severity Groups

Study ID | Dose | Mild ED | Moderate ED | Severe ED
Mean change in IIEF-EF scores from baseline
McMahon (2005) | 20 mg | 3.0 | 10.7 | 11.6
Eardley (2004) | 20 mg | 6.1 | 13.2 | 14.3
Sefte (2004) | 20 mg | 5.6 | 10.7 | 11.0
Carrier (2005) | 10 mg | 4.5 | 8.4 | 8.3
Carrier (2005) | 20 mg | 5.2 | 9.0 | 11.5
Costa, (2006) | On demand | 6.2 | 11.5 | 14.2
Costa (2006) | 3 × week | 6.4 | 11.8 | 14.6
Saylan (2006) | 20 mg | 6.3 | 8.2 | 14.8
Yip (2006) | 20 mg | 5.3 | 9.1 | 12.5
EF mean end point scores
McMahon (2005) | 20 mg | 24.4 | 23.9 | 19.0
Rajfer (2007) | 2.5 mg | 24.3 | 21.0 | 13.8
Rajfer (2007) | 5 mg | 26.2 | 21.9 | 15.5
Guo(2006) | 10 mg | 24.0 | 22.3 | 18.1
Guo(2006) | 20 mg | 23.5 | 23.0 | 21.6
Nagao (2006) | 5 mg | 25.6 | 22.7 | 15.8
Nagao (2006) | 10 mg | 26.0 | 24.0 | 20.2
Nagao (2006) | 20 mg | 25.3 | 23.0 | 21.9
Patients with normal EF at end point (%)
Eardley (2004) | 20 mg | 80 | 73 | 55
Sefte (2004) | 20 mg | 72.1 | 52.4 | 34.3
Saylan (2006) | 20 mg | 84.4 | 43.2 | 40.7
Change from baseline in SEP-3 (% of patients with successful penetration)
Young (2005) | 10 mg* | 13.1 | 46.0 | 29.2
Young (2005) | 20 mg* | 38.5 | 68.9 | 41.3
Costa, (2006) | On demand | 41.7 | 59.7 | 55.8
Costa, (2006) | 3 × week | 44.4 | 61.3 | 57.1
Rajfer (2007) | 2.5 mg | 72.5 | 56.3 | 27.4
Rajfer (2007) | 5 mg | 82.2 | 61.3 | 32.6
Nagao (2006) | 5 mg | 74.2 | 50.3 | 31.1
Nagao (2006) | 10 mg | 80.4 | 64.5 | 49.4
Nagao (2006) | 20 mg | 76.8 | 67.8 | 62.1
Change from baseline in SEP-2 (% of patients with successful penetration)
Rajfer (2007) | 2.5 mg | 90.0 | 74.8 | 38.9
Rajfer (2007) | 5 mg | 91.9 | 82.2 | 44.9
Nagao (2006) | 5 mg | 89.2 | 79.2 | 48.7
Nagao (2006) | 10 mg | 98.8 | 84.2 | 63.4
Nagao (2006) | 20 mg | 94.2 | 80.8 | 73.1

Tadalafil (20 mg) versus tadalafil (10 mg) versus tadalafil (5 mg). The effects of both tadalafil doses 20 mg and 10 mg were evaluated in eight trials. ^215,^ ^226^ – ^230,^ ^237,^ ^238^ In one of these trials, ^238^ there was an additional randomized arm in which patients received 5 mg tadalafil. Another trial ^221^ evaluated dose-response models for different doses of tadalafil (e.g. 5, 10, 25 mg).

Harms. The incidence of most reported adverse events (e.g. myalgia, nausea, back pain, diarrhea, headache, dizziness, dyspepsia, nasal congestion, facial flushing, infection, flu syndrome) across the eight trials was numerically comparable in patients receiving 20 mg versus 10 mg of tadalafil. In three trials, ^228,^ ^230,^ ^238^ the incidence of headache was slightly higher in patients receiving 20 mg tadalafil as compared with those receiving 10 mg (or 5 mg) of tadalafil. For example, in the first trial, ^228^ the proportions of patients with headache in 20 mg and 10 mg tadalafil arms were 17.1 and 8.1 percent, respectively, with a statistically significant between-arm difference (p < 0.001).

In the same trial the incidence of serious adverse events (i.e., two cases of myocardial infarction) was numerically similar in the 20 mg and 10 mg tadalafil groups (two patients in each arm). In the second trial, ^230^ numerically more patients who received 20 mg tadalafil had headache compared with those who received a 10 mg dose (8.0 versus 4.1 percent). In one trial, ^227^ compared with those who received 10 mg of tadalafil, patients receiving a 20 mg dose experienced numerically higher rates of dyspepsia (22.0 versus 9.7 percent), vasodilation (6.0 versus 3.9 percent), and accidental injury (5.0 versus 1.0 percent). The incidence of back pain was numerically slightly higher in patients receiving 20 mg versus those receiving 10 mg of tadalafil in one trial (4.0 versus 0.8 percent, respectively). ^237^ In another trial, ^215^ one patient died from an AMI after being randomly assigned to receive 20 mg tadalafil. Of the eight trials comparing the efficacy/safety profiles of 20 mg and 10 mg tadalafil, the absence or presence of serious adverse events could not be ascertained for six trials. ^221,^ ^226,^ ^227,^ ^229,^ ^230,^ ^237^

Efficacy. In five trials, ^226,^ ^227,^ ^229,^ ^237,^ ^238^ the degree of improvement in the mean change for IIEF “EF” domain and per-patient proportion of “yes” to SEP Q2–Q3 from baseline was numerically similar between 20 mg, 10 mg, and 5 mg tadalafil arms. The proportions of patients with improved erection (i.e., those who answered “yes” to GAQ) were also similar between the 10 mg and 20 mg tadalafil dose arms. ^226,^ ^227,^ ^229,^ ^237,^ ^238^ In one trial, ^215^ the magnitude of improvement with respect to the mean change in per-patient proportion of “yes” responses to SEP-Q3 from baseline was numerically greater in the 20 mg than the 10 mg tadalafil arm 24 hours post-dose (46.3 versus 25.5 percent). Similarly, in another trial, ^230^ the cumulative proportion of patients with at least one successful intercourse attempt (“yes” to SEP-Q3) attempt 30 minutes post-dose was numerically improved in patients who received 20 mg relative to those who received 10 mg of tadalafil (34.0 versus 25.0 percent). In the same trial, patients on 20 mg tadalafil had a faster erectogenic response (starting 16 minutes post-dose) than those on 10 mg of tadalafil (starting 26 minutes post-dose). ^230^

The results of one trial ^228^ were slightly inconsistent with those of others. ^215,^ ^226,^ ^227,^ ^229,^ ^230^ More specifically, patients on 10 mg (daily) of tadalafil experienced greater improvement in erectile function (based on responses to SEP-Q3, IIEF, GAQ-Q1) compared with those receiving 20 mg (on demand) of tadalafil. For example, there was a statistically significant higher mean per-patient proportion of successful intercourse attempts (i.e., based on “yes” answers to SEP-Q3) among patients receiving 10 mg tadalafil compared with those receiving 20 mg tadalafil (80 versus 67 percent, p <0.05). Similarly, the proportion of patients who answered “yes” to GAQ Q1 was higher in the 10 mg arm compared with the 20 mg arm of tadalafil (88.0 versus 73 percent, p <0.05). Furthermore, patients in the 10 mg tadalafil arm had a higher mean IIEF “EF” domain score than those in the 20 mg tadalafil arm (26.4 percent versus 23.3 percent, p <0.05).

In one study, ^221^ authors who employed logistic regression models based on patient data obtained from a randomized placebo-controlled trial, showed a statistically significant dose-dependent effect of tadalafil on the patients' outcomes as defined by responses to SEP-Q2/3 and the IIEF “EF” domain questions; more specifically, the magnitude of response increased between the 10 mg and 25 mg doses of tadalafil. Furthermore, the baseline ED severity was an important covariate in these models, indicating that patients with severe ED at baseline experienced greater incremental improvement in erectile function compared with those with moderate or mild ED at baseline.

Tadalafil (20 mg; on-demand therapy) versus tadalafil (20 mg; scheduled therapy). Two trials ^214,^ ^232^ compared the efficacy/safety of two dosing regimens of 20 mg tadalafil (on demand therapy versus scheduled therapy).

Harms. In the first trial, ^214^ the rate of any adverse events (percentage of patients with at least one adverse event) did not differ between groups who were given tadalafil either on demand or 3 times per week (21.7 versus 25.3 percent, respectively). The most frequent events in both tadalafil arms were headache (7.5 percent), dyspepsia (6.5 percent), back pain (2.7 percent), flushing (2.6 percent), and myalgia (2.5 percent). The proportion of patients who withdrew from the on-demand and the 3 times per week dosing regimens were 4.0 percent and 5.1 percent, respectively. No deaths or serious adverse events occurred during the trial. In the second trial, ^232^ the most frequent adverse events were dyspepsia, headache, back pain and myalgia, observed in two of the 20 patients.

Efficacy. One crossover trial ^214^ evaluated the relative effects of alternative dosing regimens of tadalafil (on demand versus 3 times per week) on the outcomes of ED (e.g. patient preference, mean change in IIEF “EF” domain scores and the per-patient proportion of successful intercourse attempts. The 3861 patients' responses to the treatment preference question (TPQ) showed that the on-demand regimen was preferred more frequently than the 3 times per week scheduled regimen, regardless of the sequence of the treatment regimens (57.8 versus 42.2 percent, p < 0.001). The on-demand and the scheduled 3 times per week dosing regimens were shown to be similarly efficacious with respect to the mean IIEF “EF” domain scores (24.6 versus 24.8, respectively). Similarly, the mean per-patient proportion of successful intercourse attempts (“yes” to SEP-Q3) did not differ between the on-demand and scheduled 3 times per week tadalafil groups(72.6 versus 74.4 percent).

The other trial evaluated whether 20 mg tadalafil dosing regimens (on demand versus scheduled on alternate days) differed in improving endothelium-dependent vasodilation of cavernous arteries (e.g. peak systolic velocity and flow-mediated dilation) and in producing morning erections in men diagnosed with ED as ascertained by one of the items of the SIEDY questionnaire (question: “In the last four weeks, did it ever occur that you wake up with an erection?”). ^232^ After 4 weeks of therapy, the mean increase in flow-mediated dilation (FMD) from baseline in patients treated with scheduled dosing regimen on alternate days was statistically significant (1.2 versus 8.3 percent, p < 0.05), whereas the corresponding parameter for patients treated with the on-demand therapy schedule did not change (3.3 versus 2.1 percent, p ≥ 0.05). The improvement in FMD observed in patients who had received scheduled therapy was maintained 2 weeks after the discontinuation of the therapy. There was also a statistically significant improvement in regard to morning erections observed in patients treated with the scheduled dosing regimen (90 percent of the patients; p <0.0001), but not in those treated with the on-demand dosing regimen.

Tadalafil versus sildenafil versus vardenafil. Four crossover trials compared efficacy/safety of tadalafil (20 mg) and sildenafil (25–100 mg, 50 mg, or 100 mg) in treating patients with ED. ^103,^ ^118,^ ^121,^ ^163^ One of these ^163^ additionally evaluated the efficacy/safety profile of vardenafil (20 mg).

Harms. In general, in these trials, all three therapies were well tolerated and had similar safety profiles. There were no statistically significant differences in the incidence of any adverse events between tadalafil- and sildenafil-treated groups of patients. In the tadalafil arms the proportion of patients with at least one adverse event across the four trials ranged from 27.7 percent ^163^ to 34.9 percent. ^103^ The corresponding proportion in the sildenafil arms ranged from 23.8 percent ^121^ to 34.1 percent. ^103^ In the vardenafil group, about 26.6 percent patients had at least one adverse event. ^163^ Most common events in the three therapy groups were: headache (7.8–12.2 percent), dyspepsia (3.0–6.4 percent), flushing (2.5–7.4 percent), back pain (1.8–4.8 percent), and nasal congestion (1.1–4.7 percent).

In one trial, ^103^ the incidence of serious adverse events did not differ between the tadalafil (5 patients had prostate cancer, purpura, pulmonary edema, gastric cancer) and sildenafil groups (4 patients had cardiac biopsy, chest pain, perianal abscess). Three remaining trials ^118,^ ^121,^ ^163^ did not report the occurrence or absence of serious adverse events.

The total number of withdrawals due to adverse events across the four trials ranged from two ^121^ to 12 patients. ^103,^ ^163^ The proportion of patients who withdrew from tadalafil groups ranged from one ^121^ to seven. ^103,^ ^241^ The respective proportion of patients who withdrew from the sildenafil arms ranged from one ^121^ to five. ^103,^ ^163^ Two patients withdrew due to adverse events in the vardenafil group. ^163^

Efficacy. In one trial, ^103^ the IIEF mean changes from baseline to endpoint were greater in the tadalafil than in the sildenafil arm for the domains of “Orgasmic Function” (difference between the mean changes: 0.28, 95 percent CI: 0.02–0.53) and “Sexual Desire” (difference between the mean changes: 0.19, 95 percent CI: 0.02–0.35).

In general, results of the four trials ^103,^ ^118,^ ^121,^ ^163^ regarding the measures of erectile function (i.e., mean IIEF-“EF domain” scores) were not consistent.

For example, in one trial the difference between the mean changes for IIEF “EF” domain scores did not reach statistical significance (0.51, 95 percent CI: -0.07 to 1.09). ^103^ In another trial, ^163^ there was a statistically significant higher median (percentile range 10–90) IIEF score in the tadalafil group in comparison with the vardenafil group: 30 (25–30) versus 28 (23.1–30.0), p = 0.00022. In the same trial, the differences in the mean IIEF score between the sildenafil/tadalafil and sildenafil/vardenafil groups were not statistically significant. ^163^

In one trial, ^118^ the proportion of men who had at least one successful intercourse attempt 12 or more hours post-dose was greater among patients receiving 20 mg tadalafil than in patients receiving 50 mg sildenafil (55.0 versus 29.0 percent, p <0.001). In another trial, ^103^ the mean change in per-patient proportion of successful intercourse attempts (“yes” to SEP Q3) was slightly greater in patients receiving tadalafil compared with those receiving sildenafil (difference between the mean changes: 5.2 percent, 95 percent CI: 1.8–8.6). The mean time (in hours) between dosing and sexual attempt was found to be longer for tadalafil than for sildenafil (5.6 versus 2.7, p < 0.001). ^118,^ ^121^

In the four trials, the proportion of patients preferring tadalafil (range 52.2 to 73.0 percent) was statistically significantly greater than the proportion of patients preferring sildenafil (27.0–33.7 percent) or vardenafil (20.0 percent). In one trial, ^118^ 73 percent of the patients preferred tadalafil and 27 percent preferred sildenafil (p <0.001). Similarly, the results from the two other trials ^121,^ ^163^ also indicated that more patients preferred tadalafil (66.3 and 52.2 percent, respectively) compared with those preferring sildenafil (33.7 and 27.7 percent, respectively) or vardenafil (20 percent). In one trial, ^163^ the reason for 25 percent of men preferring tadalafil to sildenafil was that they could have intercourse again the next day post-dose.

### Quantitative Synthesis - Meta-analysis of Trials

A series of meta-analyses was conducted to address the safety and efficacy of tadalafil. ^103,^ ^118,^ ^121,^ ^163,^ ^214^ – ^230,^ ^232^ – ^240^ Of the 30 eligible trials, five were excluded as potentially ineligible given the following distinct clinical features of the patients studied: patients with increased cardiovascular risk of whom 50 percent were patients with ED, ^218^ patients with radical prostatectomy, ^222^ diabetic patients, ^226^ patients with benign prostatic hypertrophy (BPH), ^233^ and patients with radical prostatic carcinoma. ^239^ In addition, two more trials were excluded because relevant numerical data needed for meta-analysis was lacking ^221^ and an inappropriate dose of tadalafil was used (2.5 mg and 5 mg). ^235^

Of the remaining 23 trials, ^103,^ ^118,^ ^121,^ ^163,^ ^214^ – ^217,^ ^219,^ ^220,^ ^223^ – ^225,^ ^227^ – ^230,^ ^232,^ ^234,^ ^236^ – ^238,^ ^240^ 16 were placebo-controlled, ^215^ – ^217,^ ^219,^ ^220,^ ^223^ – ^225,^ ^227,^ ^229,^ ^230,^ ^234,^ ^236^ – ^238,^ ^240^ and seven were active-treatment trials. ^103,^ ^118,^ ^121,^ ^163,^ ^214,^ ^228,^ ^232^ All 16 placebo-controlled randomized trials had parallel-group design and compared the efficacy and safety of tadalafil (10 mg or 20 mg or both) to placebo.

Tadalafil (any dose: 20 mg or 10 mg) versus placebo.

Efficacy. Absolute mean change from baseline in IIEF-EF score. This meta-analysis included eight trials. ^216,^ ^217,^ ^220,^ ^223,^ ^224,^ ^227,^ ^229,^ ^234^ The estimate of the pooled mean difference was 8.10 (95 percent CI: 6.98–9.22), favoring the use of tadalafil (any dose: 10 mg or 20 mg) compared with placebo in increasing the mean IIEF “EF” domain total score relative to baseline (Figure 60).

Figure 60 Absolute mean change in IIEF-EF score

Mean per-patient percentage absolute change (from baseline) in SEP-Q2. This meta-analysis included seven trials. ^216,^ ^217,^ ^220,^ ^224,^ ^227,^ ^229,^ ^234^ The estimate of the pooled mean difference was 29.34 (95 percent CI: 25.06–33.62), favoring the use of tadalafil (any dose: 10 mg or 20 mg) compared with placebo in increasing the mean per-patient percentage of SEP-Q2 relative to baseline (Figure 61).

Figure 61 Mean per-patient percent absolute change from baseline in SEP-Q2

Proportion of patients with improved erection (GAQ-Q1). This meta-analysis included eight trials. ^220,^ ^223,^ ^227,^ ^234,^ ^236^ – ^238,^ ^240^ The pooled estimate of the relative proportion of patients (i.e., RR) with improved erection (i.e., those answered “yes” to GAQ-Q1) was 2.40 (95 percent CI: 2.03–2.83), indicating a statistically significantly higher rate of improvement for patients who received any dose of tadalafil (20 mg or 10 mg) relative to the placebo-treated patients (Figure 62).

Figure 62 Improved erection (GAQ-Q1)

Tadalafil (20 mg) versus placebo.

Efficacy. Absolute mean change from baseline in IIEF-EF score. This meta-analysis included eight trials. ^216,^ ^217,^ ^220,^ ^223,^ ^224,^ ^227,^ ^229,^ ^234^ The estimate of the pooled mean difference was 8.21 (95 percent CI: 7.10–9.32), favoring the use of tadalafil (20 mg) compared with placebo in increasing the mean IIEF “EF” domain total score relative to baseline (Figure 63).

Figure 63 Absolute mean change from baseline in IIEF-EF score

Mean per-patient percentage absolute change (from baseline) on SEP-Q2. This meta-analysis included 7 trials. ^216,^ ^217,^ ^220,^ ^224,^ ^227,^ ^229,^ ^234^ The estimate of the pooled mean difference was 29.60 (95 percent CI: 25.15–34.04), favoring the use of tadalafil (20 mg) versus placebo in increasing the mean per-patient percentage of SEP-Q2 relative to baseline. (Figure 64).

Figure 64 Mean per-patient percent absolute change from baseline in SEP-Q2

Proportion of patients with improved erection (GAQ-Q1). This meta-analysis included eight trials. ^220,^ ^223,^ ^227,^ ^234,^ ^236^ – ^238,^ ^240^ The pooled estimate of the relative proportion of patients with improved erection (i.e., those who answered “yes” to GAQ-Q1) was 2.43 (95 percent CI: 2.06–2.87), indicating a statistically significantly higher rate of improvement for patients who received tadalafil (20 mg) relative to the placebo-treated patients (Figure 65).

Figure 65 Improved erection (GAQ-Q)

Harms. Proportion of patients with any adverse event (all- cause). This meta-analysis included five trials ^215,^ ^227,^ ^229,^ ^238,^ ^240^ and yielded a RR of 1.95 (95 percent CI: 1.40–2.71) with a statistically significant heterogeneity across trials (Chi^2^ _df=4_ = 15.60, p = 0.004; I^2^ = 74.4 percent) (Figure 66).

Figure 66 Any adverse events (all-cause)

We explored potential sources of this heterogeneity by examining other trial characteristics (e.g. populations, severity of ED, duration of ED, length of followup). Figure 67 presents the results based on 4 trials ^227,^ ^229,^ ^238,^ ^240^ with a 12-week followup that yielded similar effect estimates (RR range 1.45–2.08), whereas one trial ^215^ whose length of follow up was 6 weeks yielded a more inflated estimate of RR (i.e., RR = 4). After excluding this trial, the pooled estimate of RR was 1.61 (95 percent CI 1.37–1.89), indicating a statistically significantly greater rate of any adverse events in patients who received tadalafil (20 mg) relative to placebo-treated patients. There was no significant heterogeneity between the trials (Chi^2^ _df=3_ = 2.88, p = 0.41; I^2^ = 0 percent) (Figure 67). (Note that “favors” in forest plots refers to increased frequency of the event for the respective treatment arm, regardless of the desirability of the event).

Figure 67 Any adverse events (all-cause)

Tadalafil (20 mg) versus tadalafil (10 mg).

Efficacy. Mean change from baseline in IIEF-EF score. Two trials ^227,^ ^229^ compared 10 mg and 20 mg doses of tadalafil and also reported mean change in IIEF “EF” domain total score. The pooled estimate of these trials indicated that the mean increase in IIEF “EF” domain total score was not statistically different between the two dose-arms (mean difference 0.60, 95 percent CI:-0.92 to 2.11) (Figure 68)

Figure 68 Mean change from baseline in IIEF-EF score

Mean per-patient percentage absolute change (from baseline) on SEP-Q2. Two trials ^227,^ ^229^ compared 10 mg and 20 mg of tadalafil and also reported the mean per-patient percentage of SEP-Q2. The meta-analysis of these trials indicated that the mean increase in per-patient percentage of SEP-Q2 was not statistically different between the two dose-arms (mean difference 0.32, 95 percent CI: 7.53–8.18) (Figure 69).

Figure 69 Mean per-patient percent absolute change from baseline in SEP-Q2

Proportion of patients with improved erection (GAQ-Q1). Four trials ^227,^ ^229,^ ^237,^ ^238^ compared 10 mg and 20 mg of tadalafil and also reported the proportion of patients with improved erections as measured by GAQ-Q1. The meta-analysis incorporated three of these trials ^227,^ ^237,^ ^238^ and indicated that the difference observed between the rates of improvement in erection for patients who received 10 mg and 20 mg of tadalafil was not statistically significant (RR = 1.07, 95 percent CI: 0.99–1.16) (Figure 70).

Figure 70 Improved erection (GAQ-Q1)

Harms. Proportion of patients with any adverse events (all- cause). This meta-analysis included six trials, ^215,^ ^227,^ ^229,^ ^230,^ ^237,^ ^238^ which compared 10 mg and 20 mg doses of tadalafil and also reported the proportion of patients who developed at least one adverse event. The pooled summary estimate of RR indicated a statistically significant higher incidence of adverse events in patients treated with 20 mg tadalafil compared with those treated with 10 mg tadalafil (RR = 1.21, 95 percent CI: 1.05–1.38). There was no statistically significant heterogeneity across the trials (Chi^2^ _df=5_ = 6.60, p = 0.25; I^2^ = 24.3 percent) (Figure 71).

Figure 71 Any adverse events (all-cause)

Tadalafil (10 mg) versus placebo.

Efficacy. No meta-analysis was performed.

Harms. Proportion of patients with any adverse events (all-cause). This meta-analysis included four trials, ^215,^ ^227,^ ^229,^ ^238^ which compared 10 mg of tadalafil to placebo and also reported the proportion of patients who experienced at least one adverse event. The pooled summary estimate of RR indicated a statistically significant higher incidence of adverse events in patients treated with 10 mg tadalafil as compared with those treated with placebo (RR = 1.53, 95 percent CI: 1.11–2.11). The test of heterogeneity was statistically significant (Chi2df=3 = 8.99, p = 0.03; I2 = 66.6 percent) (Figure 72).

Figure 72 Any adverse events (all-cause)

After excluding a trial with a 6 week followup, ^215^ the pooled estimate of RR for the remaining three trials with 12 weeks of followup ^227,^ ^229,^ ^238^ was RR = 1.31 (95 percent CI: 1.10–1.57). The result indicated a statistically significant higher incidence of adverse events in patients treated with 10 mg tadalafil compared with those treated with placebo. There was no statistically significant heterogeneity present across the trials (Chi2df=2 = 0.01, p = 0.99; I2 = 0 percent) (Figure 73).

Figure 73 Any adverse events (all-cause)

Tadalafil versus sildenafil. No meta-analysis of the four crossover trials ^103,^ ^118,^ ^121,^ ^163^ that compared tadalafil with sildenafil was performed because the sildenafil dose/dosage varied, ^103,^ ^118,^ ^121,^ ^163^ and there was a lack of relevant efficacy outcome data such as the mean absolute change in IIEF “EF” domain total score, ^118,^ ^121,^ ^163^ per-patient percentage of successful attempts on SEP-Q2, ^118,^ ^121,^ ^163^ and the proportion of patients with improved erection on GAQ-Q1). ^118,^ ^121,^ ^163^

### Assessment of Publication Bias

Funnel plots were used to assess the extent of asymmetry (i.e., possible publication bias) present in each meta-analysis. Visual inspection of these plots did not reveal any substantial asymmetry. ^53^ (Funnel plots, Appendix G.)

## Sublingual Treatments - Apomorphine

### Literature Search

In total, 12 unique randomized controlled trials (RCTs) (11 publications) met the eligibility criteria and were included in the review. ^114,^ ^117,^ ^120,^ ^148,^ ^159,^ ^248^ – ^253^ One report ^252^ described two distinct trials (a and b).

### Overview of Trials

The trials were published between 2000 ^253^ and 2007 ^159^ inclusively, and were conducted in the US, ^251^ – ^253^ Europe, ^114,^ ^120,^ ^148,^ ^159,^ ^248^ – ^250^ the United Kingdom, ^117^ and Mexico. ^251^ The trials were supported by funds from Abbot Laboratories, ^248,^ ^250,^ ^252^ Takeda, ^248,^ ^252^ Pfizer UK, ^117,^ ^159^ and Zonagen Inc. ^251^ Funding sources were not reported for four trials. ^114,^ ^120,^ ^148,^ ^249^ The duration of followup of eight trials ^114,^ ^117,^ ^120,^ ^248,^ ^249,^ ^252,^ ^253^ ranged from 4 weeks ^249,^ ^252^ to 8 weeks. ^117,^ ^148,^ ^159,^ ^248,^ ^253^ The duration of followup for two trials could not be ascertained. ^250,^ ^251^ Of the 12 trials, four were parallel-group ^248^ – ^250,^ ^253^ and eight were crossover studies. ^114,^ ^117,^ ^120,^ ^148,^ ^159,^ ^251,^ ^252^ Of the four parallel-group RCTs, three were two-armed ^248^ – ^250^ and one was a four-armed trial. ^253^ Further information on trial characteristics is provided in (Table F-4, Appendix F).

### Populations

The included trials involved men diagnosed with erectile dysfunction (ED). The total and mean (range) numbers of patients randomly assigned to trial arms were 1975 and 179 (12–569), respectively. The inclusion criteria across the trials were adult men (age ≥ 18 years) diagnosed with ED in a stable heterosexual relationship of at least 6 months of duration. The inclusion criteria in two studies ^114,^ ^120^ were restricted either to patients with arteriogenic ^120^ or nonarteriogenic ED. ^114^ In one trial, ^249^ the inclusion criteria were restricted to patients with ED and a history of diabetes (type I or II) who had been naïve to any ED-related treatment. The enrolled patients in one trial ^159^ had to be naïve to ED drug therapy and had to have an IIEF-5 score ≤ 21.

The exclusion criteria in the majority of the included trials were spinal cord injury ^114,^ ^120,^ ^248,^ ^253^ and penile/testicular deformity. ^114,^ ^120,^ ^148,^ ^159,^ ^248,^ ^249,^ ^251^ – ^254^ Other frequently reported exclusion criteria were uncontrolled hypertension, ^114,^ ^148,^ ^251^ – ^253^ diabetes, ^148,^ ^248,^ ^252,^ ^253^ endocrine disease, ^114,^ ^248,^ ^251^ – ^253^ any major hepatic/renal disease, ^117,^ ^148,^ ^251^ prostatectomy, ^148,^ ^248,^ ^251,^ ^253^ peptic ulcers, ^159^ HIV-positivity/AIDS, ^248,^ ^252,^ ^253^ the use of nitrates, ^114,^ ^117,^ ^120,^ ^148,^ ^159,^ ^251^ a history of cancer, ^248,^ ^252,^ ^253^ and serious cardiovascular diseases (e.g. angina pectoris). ^148,^ ^159^ Only one trial failed to report exclusion criteria. ^250^

The mean age of the study participants across the included trials ranged from 35 ^250^ to 59 years. ^120^ The race of the study participants was reported in six trials. ^117,^ ^159,^ ^248,^ ^252,^ ^253^ The proportion of Caucasians across these trials ranged from 85 percent ^252^ to 99 percent. ^248^ The duration of ED was at least 3 months at study entry in all trials. The longest mean duration of ED (3.5–4.2 years) was reported in the trial by Porst et al 2007. ^159^ Most commonly reported comorbidities among the study participants were diabetes, ^114,^ ^120,^ ^148,^ ^159,^ ^248,^ ^252,^ ^253^ hypertension, ^114,^ ^120,^ ^148,^ ^159,^ ^248,^ ^249,^ ^252,^ ^253^ ischemic heart disease, ^114,^ ^249^ and coronary artery disease. ^120,^ ^159,^ ^248,^ ^252,^ ^253^ The presence or absence of comorbidities could not be ascertained from three trials. ^117,^ ^250,^ ^251^ The underlying cause of ED (i.e., etiology) in the patients was specified in three trials to be nonarteriogenic (all patients), ^114^ arteriogenic (all patients), ^120^ and various causes (patients with organic, psychogenic or mixed origin ED). ^159^ In four trials, ^114,^ ^120,^ ^249,^ ^250^ the proportion of smokers ranged from 35 percent ^249^ to 95 percent. ^114,^ ^120^ In the remaining trials this proportion could not be ascertained. ^117,^ ^148,^ ^159,^ ^248,^ ^251^ – ^253^

In seven trials ^117,^ ^159,^ ^248,^ ^249,^ ^252,^ ^253^ the authors provided baseline arm-specific distributions of the patients' sociodemographic and clinical characteristics (e.g. age, race, duration/severity of ED, comorbidities) and explicitly stated that the distribution of these characteristics between the randomized arms was generally similar. The authors of the remaining five trials ^114,^ ^120,^ ^148,^ ^250,^ ^251^ did not report this information.

### Interventions

Patients in all reviewed 12 trials ^114,^ ^117,^ ^120,^ ^148,^ ^159,^ ^248^ – ^253^ received apomorphine sublingually with a dose ranging from 2 mg ^159,^ ^248^ to 6 mg. ^251,^ ^253^ In all trials except one, ^251^ patients received apomorphine monotherapy. In this one trial, ^251^ two groups of patients received the combination of apomorphine either with phentolamine (40 mg) or with phentolamine (40 mg) plus papaverine (150 mg). One trial did not report the dose of apomorphine. ^117^

In six trials ^148,^ ^249^ – ^252^ apomorphine was given only at a fixed dose. A flexible-dose-only regimen was used in other five trials. ^114,^ ^117,^ ^120,^ ^158,^ ^248^ In one trial, ^253^ patients were randomly assigned to receive either a fixed (5 mg or 6 mg) or flexible dose (2 mg–6 mg) of apomorphine.

The duration of apomorphine treatment across the trials ranged from 4 weeks ^249,^ ^252^ to 8 weeks. ^117,^ ^148,^ ^159,^ ^248,^ ^253^ Patients in the control arms received placebo in five trials, ^248^ – ^250,^ ^252,^ ^253^ sildenafil (50–100 mg/d) in six trials, ^114,^ ^117,^ ^120,^ ^148,^ ^159,^ ^251^ and apomorphine (control dose) in two trials. ^252^ b ^253^ . An additional comparison group of patients in one trial ^251^ received a combination of phentolamine (40 mg) and papaverine (150 mg).

### Outcomes

Harms. All trials but one ^114^ reported some information on the absence and/or occurrence of adverse events: any adverse events, ^117,^ ^159,^ ^248,^ ^250,^ ^251^ serious adverse events (including death), ^117,^ ^159,^ ^248,^ ^250,^ ^251^ withdrawals due to adverse events, ^117,^ ^120,^ ^159,^ ^248,^ ^249,^ ^253^ and frequently reported (≥5 percent) specific adverse events. ^120,^ ^148,^ ^159,^ ^248^ – ^253^

Efficacy. The efficacy outcomes measured in the 11 trials varied to some degree. The most commonly measured and reported outcome across the trials was the percentage of successful intercourse attempts. ^114,^ ^117,^ ^120,^ ^148,^ ^159,^ ^248,^ ^252,^ ^253^ In four trials, the percentage of attempts resulting in erections firm enough for intercourse was also measured ^148,^ ^252,^ ^253^ . Similarly, in one trial, ^251^ the proportions of successful vaginal penetration and vaginal intercourse leading to orgasm were estimated. The above-mentioned outcomes were calculated based on the patients' and/or their partners' responses to pre-specified questions provided in home-use diaries.

In five trials, the mean IIEF score (domains of “erectile function,” “orgasmic function,” “sexual desire,” “intercourse satisfaction,” “overall satisfaction”) was used to assess the relative efficacy of apomorphine. ^117,^ ^148,^ ^159,^ ^249,^ ^253^ For example, in one trial ^117^ the primary endpoint was the mean difference in IIEF score for the “erectile function” domain, whereas secondary endpoints were mean difference IIEF scores for other domains (e.g. “orgasmic function,” “sexual desire,” “intercourse satisfaction,” and “overall satisfaction”). In another trial, ^253^ the authors provided differences between treatment-arm specific mean IIEF scores for the “erectile function,” “intercourse satisfaction,” and “overall satisfaction” domains as secondary efficacy endpoints. In this trial, ^249^ primary efficacy endpoint was a response rate defined as the proportion of patients who answered “yes” to a Global Efficacy Question (GEQ) (i.e., “Has the treatment you have been taking over the past two or four weeks improved your erections?”) combined with an improvement of ≥ 5 points in the “erectile function” domain of the IIEF.

Global Assessment Questions (GAQs) were evaluated and reported in three trials, ^117,^ ^159,^ ^251^ as a secondary response endpoint. In one trial ^117^ the endpoint was defined as the proportion of patients who answered “yes” to two GAQ questions, and in the other trial ^251^ the corresponding endpoint was treated as a continuous variable whereby responses to one GAQ were given on an ordinal scale (1 = very satisfied, 5 = very dissatisfied).

The treatment preference/satisfaction was measured and reported in three trials. ^117,^ ^120,^ ^251^ In one trial the treatment satisfaction was measured as a proportion of patients satisfied with one drug only, alternative drug only, both drugs, or none of the drugs. ^120^ In two trials, ^117,^ ^159^ the treatment-arm specific differences in IIEF “Overall Satisfaction” domain and the Erectile Dysfunction Index of Treatment Satisfaction (EDITS) questionnaire-based mean scores were used to evaluate the patient's satisfaction with treatment regimens. In their trial, Lammers et al., ^251^ employed the Visual Analogue Scale (VAS; range 0–100) to assess patients' treatment satisfaction. The endpoint was the post-treatment mean VAS satisfaction score calculated for patients in each treatment arm.

The authors of one trial ^251^ measured and reported the mean Sexual Encounter Profile (SEP) questionnaire-based overall score.

Penile rigidity was reported in two trials. ^250,^ ^251^ In one trial, ^251^ it was measured on VAS as the mean VAS rigidity (range 0–100), and in the other trial, ^250^ it was measured using a RigiScan and expressed as the percentage rigidity (i.e., percent of linear displacement of the loops due to the constant force). A post-treatment rigidity of at least 40 percent was considered a positive treatment response.

### Study Quality and Reporting

The mean (range) of Jadad's total score for the 12 included trials was 2.36 (1 ^114^ – 5 ^249^ ). Six of the 12 trials were reported to be double-blind. ^248,^ ^249,^ ^251^ – ^253^ Of these, only two trials ^249,^ ^253^ provided some description of blinding method(s) used. Only one trial reported some information on the adequacy of allocation concealment. ^249^ The adequacy of allocation concealment for the 11 remaining trials was unclear.

Of the eight crossover trials, ^114,^ ^117,^ ^120,^ ^148,^ ^159,^ ^251,^ ^252^ only one ^251^ failed to report whether a washout period was applied between the treatment periods. The length of the washout period for six trials ^114,^ ^117,^ ^120,^ ^159,^ ^252^ ranged from 24–96 hours ^252^ to 2 weeks, ^117,^ ^159^ and for one trial this duration was 4 weeks. ^148^

### Qualitative Synthesis

Apomorphine versus placebo. In total, there were five placebo-controlled trials. ^248^ – ^250,^ ^252,^ ^253^

Harms. The occurrence of any adverse events across the trials was reported poorly. In one trial, ^248^ the rate of any adverse events was numerically slightly higher in patients receiving apomorphine than in those receiving placebo (37.8 versus 24.5 percent, respectively). Another trial ^250^ reported only two patients who had experienced headaches after receiving placebo. Only one trial ^248^ explicitly stated that none of the patients died during the trial. In two trials, ^248,^ ^250^ the rate of serious adverse events did not differ between patients receiving apomorphine and placebo. In the first trial, ^248^ four patients had one or more serious adverse events. Specifically, of the two patients in the apomorphine arms (2–3 mg), one had chest infection/severe cough/cough syncope and the other one had moderate unstable angina pectoris. In the placebo arm, two patients had angina pectoris. In the second trial, ^250^ no serious adverse events had occurred. The other three trials did not report whether or not patients had experienced any serious adverse events. ^249,^ ^252,^ ^253^ In two trials, ^248,^ ^253^ the proportion of patients who withdrew due to adverse events was numerically higher in the apomorphine arms compared with placebo arms (5–10 percent versus 1 percent); in the other trial, ^249^ none of the patients withdrew due to adverse events. Other trials ^250,^ ^252^ failed to report whether any patients withdrew due to adverse events. The most common adverse event reported across trials was nausea ^148,^ ^248,^ ^249,^ ^252,^ ^253^ ranging from 7.0 percent ^252^ to 44 percent ^253^ in the apomorphine arms and from 0.4 percent ^248^ to 5.0 percent ^249^ in the placebo arms. Other commonly reported adverse events were headache, dizziness, and yawning. In general, these events had occurred numerically more frequently in apomorphine arms than in placebo arms. ^248,^ ^252,^ ^253^

Efficacy. The three trials ^248,^ ^252,^ ^253^ that measured the mean percentage of successful intercourse attempts found that this parameter was higher among patients who received apomorphine compared with those who received placebo; this finding was statistically significant. The mean percentage of successful intercourse attempts observed in apomorphine groups in these trials ranged from 38 percent ^248^ to 51 percent, ^253^ whereas the corresponding treatment response observed in the placebo groups ranged from 28 percent ^248^ to 34 percent. ^252^ The difference for each comparison between apomorphine and placebo groups in the three trials was statistically significant (p ≤ 0.01). The results for the above-mentioned endpoint, whether based on responses obtained from patients or from their partners, did not differ. ^252,^ ^253^

Two trials ^252,^ ^253^ showed that patients who received apomorphine had a statistically significant higher percentage of attempts resulting in erections firm enough for intercourse than those in placebo group. For example, in one trial ^252^ the percentages of attempts resulting in erections firm enough for intercourse in the apomorphine (3 mg) and placebo groups were 46.9 percent and 32.3 percent respectively (p < 0.001). In the other trial, ^253^ the corresponding percentages were 53.1 (apomorphine 5 mg) and 34.5 (placebo), respectively (p 0.01).

The mean IIEF score for the “Erectile Function (EF) domain” obtained from two trials ^249,^ ^253^ were not consistent. For example, in the first trial, ^249^ differences in mean IIEF “EF” domain scores between patients receiving apomorphine and placebo were not statistically significant (13.81 versus 13.24; p = 0.52). In contrast, the authors of the other trial ^253^ observed a statistically significantly greater mean IIEF score (“erectile function” domain) in the apomorphine group compared with placebo (actual mean IIEF values were not provided; p ≤ 0.01).

There was no statistically significant difference between apomorphine and placebo groups in the proportion of patients who answered “yes” to the GEQ (“Has the treatment you have been taking over the past two or four weeks improved your erections?”) combined with an improvement of ≥ 5 points in the IIEF “EF” domain (22.92 percent versus 17.31 percent, p = 0.48). ^249^

The proportion of patients with positive response on rigidity (≥ 40 percent) was numerically greater in the apomorphine compared with the placebo group (4/6 versus 0/6). ^250^

Apomorphine mono (dose/dosing 1) versus apomorphine mono (dose/dosing 2). In total, two trials compared different doses/dosing of apomorphine in patients with ED. ^252,^ ^253^

Harms. The incidence of several adverse events such as nausea, yawning, and dizziness across trials was numerically greater in patients receiving higher doses (4–6 mg) than lower doses of apomorphine (2–3 mg). ^252,^ ^253^ In one trial, ^253^ a dose-optimization schedule (2–6 mg) was associated with fewer events of nausea (30 percent of patients) than the fixed doses of apomorphine (5 and 6 mg: 38 and 49 percent of patients, respectively). Statistical test results for significance were not reported.

Efficacy. Neither of the two trials ^252,^ ^253^ identified a dose-response effect on the percentages of successful intercourse attempts and attempts resulting in erections firm enough for intercourse. For example, in one trial ^252^ the percentage of successful intercourse attempts was similar in patients who received 3 and 4 mg doses of apomorphine (48.4 versus 49.6 percent, respectively; p >0.4). In the other trial, ^253^ the percentage of successful intercourse attempts was numerically similar for patients in two dose-escalation (2–4 mg and 2–4 mg to 5–6 mg) and two fixed-dose (5 mg and 6 mg) apomorphine groups, ranging from 45.1 percent (2–4 mg) to 50.9 percent (5 mg).

Apomorphine mono versus sildenafil mono. Five trials compared the efficacy/safety of apomorphine monotherapy to that of sildenafil monotherapy ^114,^ ^117,^ ^120,^ ^148,^ ^159^

Harms. In two trials, ^117,^ ^159^ the number of patients who experienced any adverse event(s) was numerically greater in the sildenafil groups (94.0 and 35.7 percent, respectively) in comparison with the apomorphine groups (64.0 versus 21.8 percent, respectively). In another trial, ^120^ the proportions of patients with any adverse events in sildenafil and apomorphine groups were 7 percent (3/43) and 14 percent (6/43), respectively. One trial ^117^ explicitly stated that none of the patients had died during the trial and reported that five patients had had at least one serious adverse event; of these patients, three were receiving sildenafil (deterioration of arthritic shoulder in one patient and myocardial infarction/atrial fibrillation in two patients) and two were receiving apomorphine (myocardial infarction and deterioration in Dupuytren's contracture). In another trial, ^159^ serious adverse events occurred in two patients from the sildenafil group (exacerbation of chronic bursitis and stroke) and in two patients from the apomorphine group (stricture of the urethra and sudden cardiac death). The number of patients with vasodilation was numerically higher in the 50 mg sildenafil than in the 3 mg apomorphine group (6 versus 0) ^148^

In three trials, ^117,^ ^120,^ ^159^ the number of patients who withdrew due to adverse events ranged from one ^159^ to three ^117^ for the apomorphine arms and from zero ^120,^ ^159^ to two ^117^ for the sildenafil arms.

Some specific adverse events that occurred in one trial in sildenafil versus apomorphine groups were headache (16 versus 5 percent) and nausea (3.2 versus 5.6 percent). ^117^ In another trial, ^159^ the proportions of patients with headache in the sildenafil versus apomorphine groups were 10.3 versus 3.2 percent, respectively.

Efficacy. All five trials ^114,^ ^117,^ ^120,^ ^148,^ ^159^ measuring the number of successful intercourse attempts showed that the mean percentage of successful intercourse attempts was higher in patients who had received sildenafil (range 62.7–81.0 percent) compared with those receiving apomorphine (range 28.3–62.7 percent). The observed differences were statistically significant. In fact, in three trials, ^117,^ ^120,^ ^159^ the percentage of successful intercourse attempts in the sildenafil groups was about twice as that in the apomorphine groups. For example, in one trial, ^117^ the percentages of successful intercourse attempts in sildenafil and apomorphine groups were 75.1 percent (95 percent CI: 69.2–81.0) and 35.3 percent (95 percent CI: 29.4–41.3) respectively, with a mean difference of 39.7 percent (95 percent CI: 33.0–46.5) between the two groups. In the other trial, ^120^ the corresponding values of the mean percentage of successful intercourse attempts in the sildenafil (50–100 mg) and apomorphine (2–3 mg) groups, regardless the dose, were 63.7 and 32.1 percent, respectively (p < 0.01). Similarly, in another trial, ^114^ overall, patients receiving sildenafil (50–100 mg) had a statistically significantly greater mean percent of successful intercourse attempts than those receiving apomorphine (2–3 mg) (73.1 versus 62.7 percent, p = 0.0004).

The use of sildenafil was shown to be more efficacious than apomorphine in improving (i.e., increasing) IIEF scores for “erectile function” as well as for other domains (e.g. “intercourse satisfaction,” “overall satisfaction”). ^117,^ ^148,^ ^159^ For example, the mean IIEF score values for the “EF” domain in patients who received sildenafil and apomorphine were 25.2 (95 percent CI: 23.7–26.7) and 15.9 (95 percent CI: 14.4–17.3), respectively, with a mean difference of 9.3 (95 percent CI: 7.6–11.1) between the two groups. ^117^ In the other trial, ^159^ the corresponding least square mean values for the IIEF “EF” domain were 23.1 (95 percent CI: 21.8–24.4) and 15.7 (14.5–17.0), with a mean difference of 7.2 (95 percent CI: 5.5–8.8).

The proportions of patients who answered “yes” to questions 1 and 2 of GAQ (Question 1: “Compared with having no treatment at all for your erection problem, has the medication you have been taking over the past 4 weeks improved your erections?”; Question 2: “Compared with having no treatment at all for your erection problem, has the medication you have been taking over the past 4 weeks improved your ability to have sexual intercourse?”) were numerically higher in the sildenafil group than in the apomorphine group (94.8 and 93.9 percent versus 51.7 percent and 48.7 percent, respectively). ^117^ Similarly, in the other trial, ^159^ statistically significant differences were observed between patients receiving sildenafil and apomorphine with respect to GAQ-Q1 (88.7 percent versus 43.1 percent, p < 0.0001).

In the same trials, ^117,^ ^159^ the mean EDITS scores for patient satisfaction were higher in patients receiving sildenafil (82.5 and 74.0, respectively) compared with those receiving apomorphine (46.8 and 47.0, respectively).

According to results obtained from two trials, ^117,^ ^120^ more patients preferred sildenafil than apomorphine. The percent of patients who preferred sildenafil over apomorphine across these trials ranged from 65.1 percent ^120^ to 96.6 percent. ^117^ In contrast, the percentage of patients who preferred apomorphine over sildenafil ranged from 2.3 percent ^120^ to 3.4 percent. ^117^

Apomorphine (combined with phentolamine and/or papaverine) versus sildenafil.

Harms. In this trial, ^251^ the overall rates of adverse events in apomorphine combined with papaverine and phentolamine (APP), a combination of phentolamine and papaverine, and a combination of apomorphine and phentolamine, and sildenafil were 25.0, 19.1, 17.1, and 15.0 percent, respectively. Only one patient developed a serious adverse event (i.e., right nephrectomy) in the APP arm. The most frequently reported adverse events in this trial were rhinitis (4.8–15 percent) and headache (2.4–5.0 percent), the highest percentages observed in the APP arm. The authors of this trial did not report the proportion of patients in each arm that withdrew due to adverse events.

Efficacy. One trial, ^251^ found no significant differences (one-tailed p >0.05) between the combined apomorphine (either with phentolamine or phentolamine and papaverine) and sildenafil arms for most of the outcomes (e.g. mean SEP VAS rigidity, duration, and satisfaction scores, proportion of successful vaginal penetration, and mean satisfaction score based on GAQ scale).

### Quantitative Synthesis - Meta-analysis of Trials

Apomorphine mono versus placebo. Five trials ^248^ – ^250,^ ^252,^ ^253^ were considered to be eligible for meta-analysis. However, no meta-analysis could be performed because numerical information was lacking such as standard deviations (or standard errors) ^248^ – ^253^ , pre-crossover data ^252^ , mean values ^253^ for percent successful intercourse attempts and the IIEF-EF domain.

Apomorphine versus sildenafil. Trials (all crossover design) comparing the efficacy and safety profiles of apomorphine and sildenafil were not meta-analyzed because of clinical heterogeneity with respect to populations and outcomes. ^114,^ ^117,^ ^120,^ ^148,^ ^159^ For example, in two trials the patient populations were nonarteriogenic ^114^ and arteriogenic. ^120^ Types of patients studied in the third trial could not be ascertained. ^117^ The patient population of the one remaining trial ^159^ was comprised of those with ED of “mostly psychogenic,” “mostly organic,” and “mixed” etiology. Apomorphine dose(s) administered in one of the trials ^117^ were not reported.

## Injection Treatments - Intracavernosal Injection

### Literature Search

Forty-two trials (in 43 publications) met eligibility criteria as randomized trials of intracavernosal injection (IC) therapy for treatment of men diagnosed with ED. ^119,^ ^172,^ ^255^ – ^280,^ ^280^ – ^294^ One trial was reported in two publications ^261,^ ^276^ and one publication described two trials (Aversa et al. 1996; studies: a and b). ^267^

### Overview of Trials

Among the 42 unique trials, 32 used a crossover design (n = 1957; range: 7 to 240 subjects) and 10 a parallel design (n = 1074, range: 30 to 296 subjects).

### Populations

ED was primarily of physiologic origin (58 percent). Amongst ED patients, vascular disease and diabetes were the most commonly reported underlying conditions. Three trials exclusively enrolled men with previous radical prostatectomy or cystectomy (n = 159 subjects). Only eight trials reported smoking status, two trials ethnicity, and none reported body weight (e.g. body mass index).

### Interventions

IC alprostadil (PGE_1_) was evaluated alone or in combination with numerous other pharmacologic agents. One specific alprostadil combination (alprostadil plus papaverine plus phentolamine) was also tested alone or in combination with other pharmacologic agents. Other types of evaluated IC were papaverine; papaverine plus phentolamine, with or without additional sexual counseling; moxisylate; sodium nitroprusside; linsidomine; linsidomine plus urapidil; papaverine plus sildenafil; and vasoactive intestinal peptide plus phentolamine. For a full description of treatment interventions in these individual trials refer to Evidence Table F-5 (Appendix F).

### Study Quality and Reporting

Information on pharmaceutical funding was provided for nine trials. Only three studies specifically reported the use of an intention-to-treat analysis. None of the trials reported methods of allocation concealment. Study withdrawals, drop-outs or lost to followup were reported in 33 trials and were 13 percent (16 percent in crossover studies and 6 percent for parallel studies). The majority of the trials were considered to be of low quality with total Jadad score < 3. Only six of the 43 trials received a score of four, and none received a score of five. Twenty-nine trials received a score of two or less. In addition, many studies reported physiologic (e.g. degree or duration of penile rigidity) rather than clinically validated outcomes (IIEF, SEP, GAQ-Q1). No study assessed therapies beyond 12 weeks.

### Outcomes

Many of the 42 trials measured only physiologic efficacy outcomes (e.g. penile rigidity). Of the clinically relevant outcomes, more commonly reported were quality of erections achieved at home, without regard to whether the patient was able to achieve successful sexual intercourse, (e.g. “improvement” in erections, “full response,” full erection,” or “grade 4 or 5 erections”). Finally, two studies reported on whether erections were “valid for intromission,” and one on whether patients were “satisfied with treatment.” Trials that reported clinically relevant efficacy outcomes or harms are emphasized in the Outcomes section below.

### Qualitative Synthesis

Tables 12–14 illustrate the results.

Table 12 Intracavernosal Injection: Sexual Intercourse Success

Study | ED etiology | Treatment Group % (n/N) | Control Group % (n/N) | Relative Risk [95% CI]
Prostaglandins vs. Papaverine
Earle 1990 | Physiologic: 62% Idiopathic: 27% Unclear: 10% | 31% (40/129) Over 4 weeks | 33% (43/129) Over 4 weeks | 0.93 [0.65–1.33]

Table 13 Intracavernosal Injection: Improvement in Erections*

Study | ED etiology | Treatment Group % (n/N) | Control Group % (n/N) | Relative Risk [95% CI]
Prostaglandins (PgE_1_) vs. Placebo
Bechara 1997 | NR | 50 (30/60) | 0 (0/60)
Colli 1996 | Psychogenic: 53% Physiologic: 31% Mixed: 11% | 28.9 (39/135) All doses | 0 (0/45) | -
Garceau 1996 | Psychogenic: 27% Physiologic: 43.8% Mixed: 20.3% Other 8.2% | 48.1 (26/54) All doses | NR | -
Linet 1996 | Psychogenic: 13% Physiologic: 57% Mixed: 29% | A. Rigiscan 31.6 (75/237) By dose** 2.5 μg: 21% 5 μg: 31% 10 μg: 27% 20 μg: 45% | A. Rigiscan 0 (0/59) | -
B. Clinical (Full rigidity) 35 (83/237) By dose** 2.5 μg: 17% 5 μg: 27% 10 μg: 45% 20 μg: 50% | B. Clinical (Full rigidity) 0 (0/59) | -
Range of treatment improvement (%) | | 28.9–66.0 | 0 | NA
PgE_1_ vs. Papaverine
Earle 1990 | Physiologic: 62% Idiopathic: 27% Unclear: 10% | 26.4 (34/129) | 13.2 (17/129) | 2.00 [1.18–3.39]
Kattan 1991 | Physiologic: 100% | 46 (23/50) | 14 (7/50) | 3.29 [1.55–6.95]
Kunelius 1998 | NR | 40 (12/30) | 10 (3/30) | 4.00 [1.25–12.75]
Mahmoud 1992 | Psychogenic: 19% Physiologic: 66% Mixed: 15% | 80.8 (42/52) | 63.5 (33/52) | 1.27 [1.00–1.63]
Range of treatment improvement (%) | | 26.4–80.8 | 10.0–63.5 | NA
PgE_1_ vs. PgE_1_ + Papaverine
Floth 1991 | Psychogenic: 10.5% Physiologic: 92% | 60.5 (23/38) | 73.7 (28/38) | 0.82 [0.60–1.13]
PgE_1_ vs. Papaverine + Phentolamine
Bechara 1997 | NR | 50 (30/60) | 56.7 (34/60) | 0.88 [0.63–1.23]
PgE_1_ vs. Phentolamine+ PgE_1_
Aversa 1996a | Psychogenic: 100% | 20.8 (5/24) | 54.2 (13/24) | 0.38 [0.16–0.91]
Aversa 1996b | Psychogenic:100% | 30 (3/10) | 60 (6/10) | 0.50 [0.17–1.46]
Range of treatment improvement (%) | | 20.8–30.0 | 54.2–60.0 | NA
PgE_1_ vs. Trimix
Bechara 1996 | NR | 21.9 (7/32) | 50.0 (16/32) | 0.44 [0.21–0.92]
Seyam 2005 | Psychogenic: 8.9% Physiologic: 53.7% Mixed: 37.4% | 67.8 (122/180) | 66.7 (120/180) | 0.98 [0.85–1.14]
Range of treatment improvement (%) | | 21.9– 67.8 | 50.0–66.7 | NA
PgE_1_ vs. Moxisylate
Kunelius 1998 | NR | 40.0 (12/30) | 6.7 (2/30) | 6.00 [1.47–24.55]
Buvat 1998 | Psychogenic: 46% Physiologic: 26% Mixed: 28% | 85.3 (58/68) At home 81.3 (61/75) Investigator assessment | 60.7 (37/61) At home 45.7 (37/81) Investigator assessment | 1.41 [1.12–1.76] 1.78 [1.37–2.31]
PgE_1_ vs. Nitroprusside (300 μg or 400 μg)
Martinez-Piñeiro 1995 | NR | 20.0 (12/60) | 15.0 (9/60) 300 μg | 1.33 [0.61–2.93]
20.0 (7/35) | 14.3 (5/35) 400 μg | 1.40 [0.49–3.99]
PgE_1_ vs. Linsidomine
Porst 1993 | Psychogenic: 60% Physiologic: 40% | 65.0 (26/40) | 12.5 (5/40) | 5.20 [2.22–12.18]
Wegner 1995 | NR | 40.0 (16/40) | 7.5 (3/40) | 5.33 [1.68–16.89]
Wegner 1994 | NR | 30.0 (6/20) | 10.0 (4/40) | 3.00 [0.95–9.43]
Range of treatment improvement (%) | | 30.0–65.0 | 7.5–12.5 | NA
PgE_1_ vs. Linsidomine + Urapidil
Wegner 1995 | NR | 40.0 (16/40) | 25.0 (10/40) | 1.60 [0.83–3.09]
PgE_1_ vs. PgE_1_ + Lidocaine
Kattan 1995 | NR DM: 68% Low testosterone: 12% | 27.3 (6/22) | 63.6 (14/22) | 0.43 [0.20–0.91]
PgE_1_ vs. PgE_1_ + Procaine
Shramek 1994 | Psychogenic: 12.5% Physiologic: 87.5% | 66.7 (16/24) | 66.7 (16/24) | 1.00 [0.67–1.49]
Trimix vs. Trimix + Sodium Bicarbonate
Moriel 1993 | NR | 68.4 (13/19) | 78.9 (15/19) | 0.87 [0.59–1.27]
Trimix vs. Trimix + Atropine
Sogari 1997 | NR Risk factors: DM, hypertension, alcoholism, smoking, Peyronie's disease) | 45.6 (52/114) | 45.6 (52/114) | -
Papaverine + Phentolamine vs. Placebo
Bechara 1997 | NR | 56.7 (34/60) | 0 (0/60) | -
Papaverine + Phentolamine + Sexual counseling vs. Papaverine + Phentolamine
Van der Windt 2002 | Psychogenic: 35.7% Physiologic: 11.4% Mixed: 34.3% | 84 (subjective erection score, range 0–100) | 79 (subjective erection score, range 0–100) | -
PgE_1_ + Papaverine vs. Papaverine + Phentolamine
Floth 1991 | Psychogenic: 12.3% Physiologic: 100% (Patients could have both) | 77.6 (38/49) | 57.1 (28/49) | 1.36 [1.02–1.81]
Papaverine vs. Moxisylate
Kunelius 1998 | NR | 10.0 (3/30) | 7.0 (2/30) | 1.50 [0.27–8.34]
Moxisylate vs. Placebo
Costa 1993 | Psychogenic: 32% | 86.9 (53/61) | 27.9 (17/61) | 3.12 [2.06–4.72]
Vasoactive Intestinal Polypeptide + Phentolamine vs. Placebo
Sandhu 1999 | Physiologic: 47% Mixed: 53% (Dose assessment phase) Results: Phase 1–2 combined. Phase 1 criteria met by 133 patients and phase 2 criteria met by 126 patients (94.7%) ITT population: 172 of 195 of those who received at least one injection of active treatment and placebo | Erections suitable for intercourse 25 μg dose: 75.1% (1417/1886 injections) 2 mg dose: 66.5% (257/386 injections) [underlined: ITT analysis] 25 μg dose: 73.7% (1576/2137 injections) 2 mg dose: 69.1% (397/574 injections) | Erections suitable for intercourse 25 μg dose: 12.1% (45/373 injections) 2 mg dose: 10.3% (8/78 injections) [underlined: ITT analysis] 25 μg dose: 12.9% (55/426 injections) 2 mg dose: 13.7% (16/116 injections) | p <0.001 p <0.001 p <0.001 p <0.001
Timing of PgE1 and/or use in post-prostatectomy populations PgE_1_(early intervention) vs. PgE_1_ (late intervention): post non-nerve-sparing radical prostatectomy
Gontero 2003 | All men had prostate cancer† | 72.2 (26/36) | 43.2 (16/37) | 1.67 [1.10–2.54]
PgE_1_ vs. No Treatment: post-nerve-sparing radical retropubic prostatectomy
Montorsi 1997 | All men had prostate cancer† | 66.7 (8/12) | 20 (3/15) | 3.33 [1.12–9.90]
PgE_1_ + Sexual Counseling vs. PgE_1_: post-nerve-sparing radical retropubic prostatectomy or cystectomy
Titta 2006 | Men had either prostate and/or bladder cancer† | Mean IIEF score 26.6 (before surgery) 8.4 (before ICI) 23.4 (3 months after surgery) 26.5 (18 months after surgery) 75.8 (22/29) No ED at end of study | Mean IIEF score 26.1 (before surgery) 8.4 (before ICI) 21.7 (3 months after surgery) 24.3 (18 months after surgery) 50.0 (14/28) No ED at end of study | - - p <0.05 1.52 [0.99–2.32]

* Defined as full erection or “positive response,” Grade 4/5 erections, or erections sufficient for intercourse or Rigiscan assessment ≥70% rigidity base or tip lasting ≥10 minutes

** Numbers extracted from graph

† All men were potent or had normal International Index of Erectile Dysfunction (IIEF) scores at baseline

†† Percentage of sexual situations producing an erection

Table 14 Intracavernosal Injection: Patients with Adverse Events

Study | Adverse Events | Treatment Group % (n/N) | Control Group % (n/N) | Absolute Risk Difference [95% CI]
Prostaglandins (PgE_1_) vs. Placebo
Bechara 1997 | Pain | 35.0 (21/60) | 0 | -
Linet 1996 | Penile pain Priapism | 22.7 (54/237) 2.5 (6/237) | NR NR | - -
Vanderschueren 1995 | Penile pain | 11.7 (74/630) | 10.9 (23/210) | 1.0 [-4.0, 6.0]
von Heyden 1993 | Penile pain/burning sensation | 13.3 (18/135) | NR | -
Range of reported pain/discomfort (%) | | 11.7–35.0 | 0–10.9 | NA
Bechara 1997 | Prolonged erection | 15.0 (9/60) | 0 (0/60) | -
von Heyden 1993 | Hematoma | 1.5 (2/135) | NR | -
Colli 1996 | Treatment-related | 2.2 (3/135) | 2.2 (1/45) | -
von Heyden 1993 | Treatment-related | 16.3 (22/135) | NR | -
PgE_1_ vs. Papaverine
Earle 1990 | Pain during injection | 8.5 (11/129) | 4.7 (6/129) | 4.0 [-2.0, 10.0]
Kattan 1991 | Pain during injection | 46.0 (23/50) | 44.0 (22/50) | 2.0 [-17.0, 21.0]
Mahmoud 1992 | Penile pain | 11.5 (6/52) | 32.7 (17/52) | -21.0 [-37.0, -6.0]
Range of reported pain/discomfort (%) | | 8.5–46.0 | 4.7–44.0 | NA
Earle 1990 | Prolonged erection | 0 | <1 (1/129) | -
Kattan 1991 | Priapism | 0 | 0 | -
Kunelius 1998 | Prolonged erection | 10.0 (3/30) | 6.7 (2/30) | 3.0 [-11.0, 17.0]
Mahmoud 1992 | Priapism | 0 | 0 | -
Range of prolonged erection/priapism (%) | | 0–10.0 | 0–6.7 | NA
Kattan 1991 | Dizziness/headache | 2.0 (1/50) | 4.0 (2/50) | -2.0 [-9.0, 5.0]
PgE_1_ vs. Papaverine + PgE_1_
Floth 1991 | Pain | 34.2 (13/38) | 18.4 (7/38) | 16.0 [-4.0, 35.0]
Prolonged erection | 0 | 10.5 (4/38) | -
PgE_1_ vs. Papaverine + Phentolamine
Bechara 1997 | Pain | 35.0 (21/60) | 15.0 (9/60) | 20.0 [5.0–35.0]
Prolonged erection | 15.0 (9/60) | 18.3 (11/60) | -3.0 [-17.0, 10.0]
PgE_1_ vs. Phentolamine+ PgE_1_
Aversa 1996a | Prolonged erection | 4.2 (1/24) | 4.2 (1/24) | -
PgE_1_ vs. Trimix
Bechara 1996 | Pain | 40.6 (13/32) | 12.5 (4/32) | 28.0 [8.0–49.0]
Seyam 2005 | Pain | 17.3 (31/179) | 14.4 (26/179) | -3.0 [-11.0, 4.0]
Range of reported pain/discomfort (%) | | 14.4–40.6 | 12.5–17.8 | NA
Seyam 2005 | Priapism | <1.0 (1/179) | 5.0 (9/170) | -5.0 [-8.0, -1.0]
PgE_1_ vs. Moxisylate
Buvat 1998 | Pain during injection: clinic Pain during injection: home Pain during erection: clinic Pain during erection: home Pain after erection: clinic Pain after erection: home Prolonged erection: clinic Prolonged erection: home Bleeding: clinic Bleeding: home Dizziness/hypotension: home | 13.3 (10/75) 25.0 (17/68) 17.3 (13/75) 23.5 (16/68) 6.7 (5/75) 19.1 (13/68) 5.3 (4/75) 4.4 (3/68) 2.7 (2/75) 14.7 (10/68) 1.5 (1/68) | 14.8 (12/81) 14.8 (9/61) 2.5 (2/81) 4.9 (3/61) 0 (0/81) 4.9 (3/61) 0 (0/81) 1.6 (1/61) 2.5 (2/81) 4.9 (3/61) 8.2 (5/61) | -1.0 [-12.0, 9.0] 10.0 [-3.0, 24.0] 15.0 [6.0–24.0] 19.0 [7.0–30.0] - 14.0 [3.0–25.0] - 3 .0 [-3.0, 9.0] 0.0 [-5.0, 5.0] 10.0 [0.0–20.0] -7.0 [-14.0, 1.0]
Kunelius 1998 | Prolonged erection | 10.0 (3/30) | 3.3 (1/30) | 7.0 [-6.0, 19.0]
PgE_1_ vs. Nitroprusside (100 μg, 300 μg or 400 μg)
Martinez-Piñeiro 1995 | Pain during injection Dizziness Hematoma | 6.7 (7/105) 3.8 (4/105) 1 subject | 0 6.7 (7/105) 1 subject | 7.0 [2.0–12 .0] -3.0 [-9.0, 3.0] -
PgE_1_ vs. Linsidomine
Porst 1993 | Penile pain | 17.5 (7/40) | NR | -
Wegner 1995 | Pain during injection | 7.5 (3/40) | 2.5 (1/40) | 5.0 [-4.0, 14.0]
Range of reported pain/discomfort (%) | | 7.5–17.5 | NA | NA
Porst 1993 | Moderate/severe headache | NR | 7.5 (3/40) | -
PgE_1_ vs. Linsidomine + Urapidil
Wegner 1995 | Pain during injection Serve hypotension | 7.5 (3/40) 0 | 7.5 (3/40) 12.5 (5/40) | - -
PgE_1_(fast injection) vs. PgE_1_(slow injection)
Gherchiu 1996 | Pain during injection | 54.5 (6/11) | 18.2 (2/11) | 36.0 [-1.0, 74.0]
PgE_1_ vs. PgE_1_ + Local Anesthetic
Kattan 1995 | Pain | 86.4 (19/22) | 45.4 (10/22) Lidocaine | 41.0 [16.0–66.0]
Shramek 1994 | Pain, moderate to severe | 83.3 (20/24) (11 patients with severe ED) | 62.5 (15/24) + Procaine (4 patients with severe ED | 21.0 [-4.0, 45.0]
Range of reported pain/discomfort (%) | | - | - | NA
PgE_1_ vs. PgE_1_ + Sodium Bicarbonate
Godschalk 1996 | Pain | 80.0 (8/10) | 70.0 (7/10) | 10.0 [-28.0, 48.0]
PgE_1_ + Papaverine vs. Papaverine + Phentolamine
Floth 1991 | Pain Prolonged erection | 16.3 (8/49) 8.2 (4/49) | 0 8.2 (4/49) | - -
Trimix vs. Trimix + Sodium Bicarbonate
Moriel 1993 | Pain/discomfort | 57.9 (11/19) | 5.3 (1/19) | 53.0 [28.0–77.0]
Trimix vs. Trimix + Atropine
Sogari 1997 | Pain | 50.0 (57/114) | 55.3 (63/114) | -5.0 [-18.0, 8.0]
Papaverine +Phentolamine vs. Placebo
Bechara 1997 | Pain Prolonged erection | 15.0 (9/60) 18.3 (11/60) | 0 0 | - -
Papaverine + Phentolamine + Sexual Counseling vs. Papaverine + Phentolamine
Van der Windt 2002 | 12% discontinued because of prolonged erection Priapism: 3 patients Hematoma: 4 patients Curvature of the penis: 1 patient AE similar between groups | | | -
Papaverine vs. Moxisylate
Kunelius 1998 | Prolonged erection | 6.7 (2/30) | 3.3 (1/30) | 3.0 [-8.0, 14.0]
Moxisylate vs. Placebo
Costa 1993 | Prolonged erection Mild pain Faintness (normal BP) Hypotension, nausea, or bradycardia Hot flushes Vagal shock after sharp pain during injection | 1.6 (1/61) 3.3 (2/61) 3.3 (2/61) 1.6 (1/61) 1.6 (1/61) 0 | 0 0 0 0 0 1.6 (1/61) | - - - - - -
Vasoactive Intestinal Polypeptide + Phentolamine vs. Placebo
Sandhu 1999 | Bruising Bleeding at injection site Pain on injection Urethral bleeding Priapism Flushing Headache Palpitation Tachycardia | 43.1 (84/195) 20.5 (40/195) 4.6 (9/195) 12.3 (24/195) <1.0 (1/195) 74.4 (145/195) 3.6 (7/195) 7.7 (15/195) 5.1 (10/195) | 12.3 (24/195) 5.1 (10/195) 8.2 (16/195) 2.6 (5/195) 0 13.3 (26/195) 1.5 (3/195) 0 <1.0 (1/195) | 31.0 [22.0–39.0] 15.0 [9.0–22.0] -4.0 [-8.0, 1.0] 10.0 [5.0–15.0] - 61.0 [53.0–69.0] 2.0 [-1.0, 5.0] - 5.0 [1.0–8.0]
Timing of PgE1 PgE_1_(early intervention) vs. PgE_1_ (late intervention): post non-nerve-sparing radical prostatectomy
Gontero 2003 | Prolonged erection | 8.3 (3/36) | 0 (0/37) | -
PgE_1_ vs. No Treatment: post-nerve-sparing radical retropubic prostatectomy
Montorsi 1997) | Prolonged erection Hematoma | 6.7 (1/15) 13.3 (2/15) | 0 (0/15) 0 (0/15) | - -
PgE_1_ + Sexual Counseling vs. PgE_1_: post-nerve-sparing radical retropubic prostatectomy or cystectomy
Titta 2006 | Moderate pain Severe pain Prolonged erection Hematoma Priapsim Nodule | 34.5 (10/29) 13.8 (4/29) 17.2 (5/29) 6.9 (2/29) 0 0 | 42.9 (12/28) 10.7 (3/28) 17.8 (5/28) 10.7 (3/28) 0 0 | -8.0 [-34.0, 17.0] 3.0 [-14.0, 20.0] -1.0 [-20.0, 19.0] -4.0 [-19.0, 11.0] - -
Vasoactive Intestinal Polypeptide + Phentolamine (2 arms) vs. Placebo
Dinsmore 1999 | Bruising Bleeding at injection site Pain on injection Urethral bleeding Priapism Flushing | 5.5–7.2 (range) 4.0–4.6 (range) 0 2.2–2.5 (range) 0.1 47.0–50.0 (range) | 5.1 3.0 7.7 0.4 0 9 | - - - - - -
Papaverine followed by Sildenafil vs. Sildenafil followed by Papaverine
Viswaroop 2005 | Priapism Headache Blurred vision Dyspepsia | Both arms combined 10.0 (5/50) 4.0 (2/50) 2.0 (1/50) 2.0 (1/50) | | - - - -

PGE_1_ versus no treatment. One trial, involving men who had undergone nerve-sparing radical retropubic prostatectomy, compared efficacy and harms of PGE1 to those of no treatment. ^265^

Harms. In total, 6.7 percent and 13.3 percent of participants treated with PGE_1_ reported prolonged erection and hematoma, respectively. No untreated participants reported these adverse event s.

Efficacy. In total, 66.7 percent of participants receiving PGE_1_ had improved erections versus 20 percent of those who did not receive any treatment. The absolute risk difference (RD) between the two groups was 47 percent (95 percent CI: 13–80).

PGE_1_ versus placebo. Six trials compared efficacy and/or harms of PGE1 versus placebo. ^266,^ ^268,^ ^274,^ ^281,^ ^282,^ ^292^

Harms. Penile pain was reported in four trials and occurred numerically more commonly in participants treated with PGE_1_. In one trial, penile pain was reported by 22.7 percent of the participants treated with PGE_1_ ^271^ and in another in 13.3 percent of the participants. ^282^ Neither study reported data on pain for the placebo groups. A third trial reported pain to have occurred in 35 percent of the participants who received PGE_1_ versus 0 percent of the placebo-treated participants ^266^ The fourth trial observed similar proportions of patients with pain between the treatment groups (PGE_1_: 11.7 percent versus placebo: 10.9 percent). ^274^ Prolonged erection or priapism was reported by 15 percent ^266^ and 2.5 percent ^271^ of the PGE_1_ -treated participants. In placebo-treated subjects, none of the participants had priapism in the first trial, and no priapism-related data were reported for the second trial. In a single trial, hematoma was reported for 1.5 percent of injections with PGE_1_, with no data reported for the placebo group. ^282^

Efficacy. In four crossover trials, between 28.9 and 66 percent of participants reported improved erections in the PGE_1_ treatment groups. In two of these trials, placebo-treated participants did not experience improved erections ^266,^ ^268^ The other two trials did not report any outcomes data for the placebo groups. ^281,^ ^292^

In one parallel trial, none of the placebo-treated participants reported improved erections, as compared with 35 percent of the participants treated with PGE_1_. The observed pattern conformed a dose-response trend (17 percent with 2.5μg PGE_1_, 27 percent with 5μg, 45 percent with 10μg, and 50 percent with 20μg). ^271^

PGE_1_ versus PGE_1_ (comparison of timing of treatment initiation or dose delivery). One trial compared the harms related to fast versus slow PGE1 injection (i.e., 5-second injection versus 60-second injection). ^270^ A second trial, involving men who had undergone non-nerve-sparing radical prostatectomy, compared the efficacy and harms of early versus late post-prostatectomy PGE1 treatment (i.e., 1–3 months post-operatively versus 4–12 months post-operatively). ^256^

Harms. In the first trial, 54.5 percent of those receiving fast PGE_1_ injections reported pain during injection versus 18.2 percent of those receiving slow injections. ^270^ In the second trial, 8.3 percent of participants who received early PGE_1_ treatment reported prolonged erections versus 0 percent of those who received late PGE_1_ treatment. ^256^

Efficacy. In total 72.2 percent of participants receiving early PGE_1_ treatment reported improved erections versus 43.2 percent of those receiving late PGE_1_ treatment. ^256^

PGE_1_ versus papaverine. Four trials compared the efficacy and/or harms of PGE1 versus papaverine, ^287,^ ^288,^ ^291,^ ^293^ Only one trial of intracavernosal injection evaluated the outcome of sexual intercourse success. ^291^

Harms. In three trials that reported penile pain, two ^288,^ ^291^ showed statistically nonsignificant differences between PGE_1_ and papaverine (8.5 percent versus 4.7 percent, and 46 versus 44 percent, respectively). ^288,^ ^291^ The third trial reported more frequent occurrence of pain in the papaverine participants (32.7 percent versus 11.5 percent, RD 21 percent, 95 percent CI: 6.0–37.0). ^287^ All four trials reported the incidence of priapism. In one trial, this occurred in 10 percent of the participants treated with PGE_1_ versus 6.7 percent of those treated with papaverine. ^293^ In two trials no cases of priapism occurred in either treatment group. ^287,^ ^288^ In the fourth trial, no priapism occurred among PGE_1_-treated subjects versus 0.8 percent of the participants among papaverine-treated subjects. ^291^

Efficacy. In one trial ^291^ , the proportions of PGE_1_- and papaverine-treated patients achieving at least one successful intercourse attempt over 4 weeks of treatment were similar (31 percent versus 33 percent).

In four trials, from 26.4 to 80.8 percent of the PGE_1_-treated participants reported improved erections, as compared with 10 to 63.5 percent of papaverine-treated subjects. The estimates of RR favouring PGE_1_ over papaverine were statistically significant in three trials ^288,^ ^291,^ ^293^ and marginally significant in the fourth trial. ^287^

PGE_1_ plus papaverine versus phentolamine plus papaverine. One trial compared efficacy and harms of papaverine plus PGE1 versus papaverine plus phentolamine. ^289^

Harms. In total, 16.3 percent of the papaverine plus PGE_1_ participants reported pain versus 0 percent of the papaverine plus phentolamine participants. Approximately 8 percent of the participants in each treatment group reported prolonged erection.

Efficacy. In total, 77.6 percent of participants allocated to papaverine plus PGE_1_ reported improved erections versus 57.1 percent of participants allocated to papaverine plus phentolamine.

PGE_1_ versus papaverine plus phentolamine. One trial compared the efficacy and harms of PGE1 versus papaverine plus phentolamine. ^266^

Harms. In total, 35 percent of PGE_1_ participants reported pain versus 15 percent of papaverine plus phentolamine participants. There was no difference in prolonged erections between the two treatments (15.0 percent versus 18.3 percent; RD -3.0 percent, 95 percent CI: -17.0 to 10.0)

Efficacy. In total, 50 percent of participants treated with PGE_1_ reported improved erections versus 56.7 percent of those treated with papaverine plus phentolamine.

PGE_1_ versus trimix. (see papaverine plus phentolamine plus PGE_1_ versus PGE_1_ below)

PGE_1_ versus moxisylate. Two trials compared the efficacy and harms of PGE1 to moxisylate. ^262,^ ^293^ In both trials, PGE1 was shown to be more effective than moxisylate.

Harms. In the first study, compared with participants in the moxisylate group, those in the PGE_1_ group experienced the following events more frequently: pain during injection (14.8 versus 25 percent), pain during erection (4.9 versus 23.5 percent), pain after erection (4.9 versus 19.1 percent), prolonged erection (1.6 versus 4.4 percent), and bleeding (4.9 versus 14.7 percent), whereas, the occurrence of dizziness/hypotension was numerically more common in moxisylate-treated participants (8.2 versus 1.5 percent). Not all differences were statistically significant. In the second study, prolonged erection appeared more common in the participants treated with PGE_1_ (3.3 versus 10 percent)

Efficacy. In the first trial, 85.3 percent of the participants treated with PGE_1_ reported improved erections versus 60.7 percent of the moxisylate-treated participants. ^262^ In the second trial, the rates of improved erection in PGE_1_ and moxisylate groups were 40 percent and. 6.7 percent, respectively. ^293^

PGE_1_ versus sodium nitroprusside. One trial compared the efficacy and harms of PGE1 with three different doses of nitroprusside (100μg, 300μg, or 400μg). ^278^

Harms. In total, 6.7 percent of the participants in PGE_1_ group reported pain during injection versus 0 percent of those in each of the nitroprusside group. About 4.0 percent of the participants treated with PGE_1_ reported dizziness versus 10, 8 and 3 percent for each of the nitroprusside groups(100μg, 300μg, and 400μg, respectively).

Efficacy. In total, 20 percent of the participants treated with PGE_1_ reported full rigidity. Nitroprusside 100μg was reported to be ineffective in producing erections. In the 300μg and 400μg nitroprusside groups, 15 percent and 14.3 percent of the participants, respectively had full rigidity.

PGE_1_ versus linsidomine. Three trials compared the efficacy and harms of PGE1 to linsidomine. ^273,^ ^279,^ ^284^

Harms. In one trial, 17.5 percent of participants receiving PGE_1_ reported penile pain. Similar data for the linsidomine-treated subjects was not provided. In the linsidomine group, moderate to severe headache was reported by 7.5 percent of the subjects. ^284^ In a second trial, 7.5 percent of PGE_1_ participants reported pain during injection versus 2.5 percent of linsidomine subjects. ^273^

Efficacy. Between 30 and 65 percent of the participants treated with PGE_1_ had improved erections compared with 7.5–12.5 percent of those treated with linsidomine.

PGE_1_ versus linsidomine plus urapidil. One trial compared the efficacy and harms of PGE1 to linsidomine plus urapidil. ^273^

Efficacy. In total, 40 percent of participants randomly assigned to PGE_1_ therapy reported improved erections versus 25 percent of those randomly assigned to linsidomine plus urapidil therapy.

Harms. In total, 7.5 percent of participants in each treatment group reported pain during injection, while 0 percent of those receiving PGE_1_ and 12.5 percent of those receiving linsidomine plus urapidil reported severe hypotension.

PGE_1_ versus PGE_1_ plus lidocaine. One trial compared the efficacy and harms of PGE1 injections with or without lidocaine.

Harms. The proportions of participants reporting pain in PGE_1_ plus lidocaine versus PGE_1_ only groups were 45.4 percent and 86.4 percent, respectively.

Efficacy. In total 63.6 percent of the participants allocated to PGE_1_ plus lidocaine reported improved erections versus 27.3 percent of those allocated to PGE_1_ alone.

PGE_1_ versus PGE_1_ plus procaine. One trial compared the efficacy and harms of PGE1 injections with and without procaine (10mg or 20mg). ^280^

Harms. Of participants allocated to PGE_1_ plus procaine, 62.5 percent reported moderate to severe pain compared with 83.3 percent of those allocated to treatment with PGE_1_ only. The occurrence of severe pain was reported by 16.6 percent versus 45.8 percent of the participants, respectively.

Efficacy. In total, 66.7 percent of those assigned to receive PGE_1_ plus procaine reported improved erections versus 66.7 percent of those assigned to receive PGE_1_ only.

PGE_1_ versus PGE_1_ plus sodium bicarbonate. One trial compared the harms of PGE1 injections with or without sodium bicarbonate. ^269^

Harms. In total, 70 percent of participants assigned to the PGE_1_ plus sodium bicarbonate group reported pain versus 80 percent of those assigned to the PGE_1_ group. The incidence of pain in PGE_1_ plus sodium bicarbonate group was reduced compared with PGE_1_ alone group but the between-group difference was not statistically significant (70 percent versus 80 percent, RD -10 percent, 95 percent CI: -48.0–28.0).

Efficacy. The efficacy was not reported

PGE_1_ plus sexual counseling plus sildenafil versus PGE_1_ plus sildenafil. One trial compared the efficacy and harms of PGE1 plus sexual counseling plus adjunctive open label oral sildenafil versus PGE1 plus adjunctive open label sildenafil in men who had undergone non-nerve sparing radical retropubic prostatectomy or radical cystectomy. ^294^

Harms. The frequency of adverse events was similar for PGE_1_ plus counseling plus sildenafil versus PGE_1_ plus sildenafil groups, including moderate pain (34.4 percent versus 42.8 percent), severe pain (13.7 percent versus 10.7 percent), prolonged erection (17.2 percent versus 17.8 percent), and hematomas (6.9 percent versus 10.7 percent). There were no withdrawals among the participants allocated to PGE_1_ plus counseling plus sildenafil. In contrast, 29 percent of those treated with PGE_1_ plus sildenafil withdrew (3 of 8 withdrawals were due to prolonged pain after injections).

Efficacy. Mean score on the IIEF “EF domain” after 18 months of treatment was significantly higher in men allocated to PGE_1_ plus counseling plus sildenafil versus those allocated to PGE_1_ plus sildenafil (26.5 versus 24.3, p <0.05).

Papaverine versus placebo. None of the identified studies compared papaverine monotherapy to placebo. One trial reported the efficacy and harms of papaverine plus PGE1 versus PGE1 alone. ^289^ Papaverine plus PGE1 was not shown to be more effective and it was associated with more frequent pain than PGE1 alone.

Harms. In total 34.2 percent of participants allocated to papaverine plus PGE_1_ reported pain versus 18.4 percent of those allocated to PGE_1_ alone. The incidence of prolonged erection was reported by 15 percent and 18.3 percent of the participants in each group, respectively.

Efficacy. In total, 73.7 percent of participants allocated to papaverine plus PGE_1_ reported improved erections versus 60.5 percent of those allocated to PGE_1_ alone.

Papaverine versus PGE_1_ (see PGE_1_ versus papaverine, above).

Papaverine versus moxisylate. One trial compared the efficacy and harms associated with the use of papaverine versus moxisylate. ^293^

Harms. In total, 6.7 percent of the papaverine-treated participants reported prolonged erection versus 3.3 percent of the moxisylate-treated participants (p ≥ 0.05).

Efficacy. In total, 10 percent of the papaverine-treated participants reported improved erections versus 7 percent of the moxisylate-treated participants (p ≥ 0.05).

Papaverine followed by sildenafil versus sildenafil followed by papaverine. One trial compared the efficacy and harms for a single 30 mg dose of papaverine followed by a single 50 mg dose of sildenafil versus a single 50 mg sildenafil dose followed by 30 mg papaverine. ^172^

Harms. Adverse events were reported for both treatment groups combined, including priapism (10 percent), headache (4 percent), blurred vision (2 percent), and dyspepsia (2 percent).

Efficacy. Data on clinically relevant outcomes were not reported.

Moxisylate versus placebo. One trial compared the efficacy and harms for moxisylate versus placebo. ^285^

Harms. Participants receiving moxisylate reported prolonged erection (1.6 percent), pain (3.3 percent), faintness (3.3 percent), hypotension/nausea/bradycardia (1.6 percent) and hot flushes (1.6 percent). Though no participants receiving placebo experienced any of these side effects, these differences were not statistically significant.

Efficacy. In total, 86.9 versus 27.9 percent of moxisylate and placebo participants, respectively, reported improved erections (RR = 3.12, 95 percent CI: 2.06–4.72).

Moxisylate versus PGE_1_ (see PGE_1_ versus moxisylate, above).

Moxisylate versus papaverine (see papaverine versus moxisylate, above).

Phentolamine plus PGE_1_ versus PGE_1_. Two trials compared phentolamine plus PGE1 versus PGE1 alone for efficacy and/or harms (Aversa 1996; studies: a and b). ^267^

Harms. In the single trial that reported prolonged erection, ^267^ 4.2 percent of participants in each treatment group reported this adverse effect.

Efficacy. In the first trial, 54.2 percent of participants randomized to phentolamine plus PGE_1_ reported improved erections versus 20.8 percent of those randomized to PGE_1_. ^267^ The corresponding proportions reported for the other study were 60 versus 30 percent, respectively. ^267^

Papaverine plus phentolamine versus placebo. One trial compared the efficacy and harms of papaverine plus phentolamine versus placebo. ^266^

Harms. In total, 15 and 18.3 percent of the participants randomized to papaverine plus phentolamine reported the occurrence of pain and prolonged erection, respectively. None of the participants in placebo group experienced these adverse events.

Efficacy. In total, 56.7 percent of participants randomized to papaverine plus phentolamine reported improved erections versus 0 percent of those randomized to placebo.

Papaverine plus phentolamine versus papaverine plus phentolamine plus sexual counseling. One trial compared the efficacy and harms of papaverine plus phentolamine versus papaverine plus phentolamine plus sexual counseling. ^257^

Harms. Results for harms in this study were pooled for the two treatment groups. 12 percent of the men discontinued the treatment due to prolonged erection. Priapism was reported in three (4.3 percent), hematoma in four (5.7 percent), and curvature of the penis in one participant (1.4 percent).

Efficacy. The mean values on a self-rated erections score (scale 0–100) for papaverine plus phentolamine versus papaverine plus phentolamine plus sexual counseling groups were 79 versus 84 percent, respectively.

Trimix versus PGE_1_. Two trials compared the efficacy and harms of trimix versus PGE1 alone. ^255,^ ^272^ In the first trial, 32 men (mean age: 61 years) with ED of at least 6 months of duration (etiology not reported) refractory to in-clinic injection of papaverine plus phentolamine, were randomized in a crossover fashion to 40μg of PGE1 versus 17.64 mg papaverine plus 0.58 mg phentolamine plus 5.8μg PGE1. ^272^ Another trial enrolled 180 men (mean age: 51 years) with ED at least 6 months' duration, predominately of organic cause, of whom 20 percent had complete ED. ^255^ Men in this trial were randomized in a crossover fashion to 20μg of PGE1 alone versus one of nine different dose combinations of papaverine (range 5mg–20mg) plus phentolamine (1 mg) plus PGE1 (2.5–10μg).

Harms. In the first trial, 12.5 percent of participants randomized to trimix reported pain versus 40.6 percent of those allocated to PGE_1_. ^272^ . In the second trial, corresponding proportions were 14.4 percent (for trimix) versus 17.3 percent (for PGE_1_). ^255^ Only the second trial reported data on priapism, which occurred in 5.0 percent of participants allocated to trimix versus 0.6 percent of those allocated to PGE_1_. ^255^

Efficacy. About half (50 percent) of the participants randomized to trimix reported grade 4 or 5 erections versus 21.9 percent of those randomized to PGE_1_ alone. ^272^

There was no difference between trimix and PGE_1_ for erections of either grade 4 or 5 (trimix: 66.7 percent versus PGE_1_: 67.8 percent), or for improvement in self-rated erection compared with home (trimix: 83.2 percent versus PGE_1_: 84.9 percent, p = 0.85). There was no statistically significant difference in efficacy outcomes between PGE_1_ and any individual trimix dose combination. ^255^

Trimix plus atropine versus trimix. One trial compared the efficacy and harms of trimix versus trimix plus atropine. ^264^ Addition of atropine to trimix did not reduce pain or improve erections compared with trimix alone.

Harms. In total 55.3 percent of participants allocated to trimix plus atropine reported pain versus 50 percent of those allocated to trimix alone.

Efficacy. Each treatment group reported improved erections in 45.6 percent of the participants.

Trimix plus sodium bicarbonate versus trimix. One trial compared the efficacy and harms of trimix injections with and without sodium bicarbonate. ^283^

Harms. In total pain was reported by 5.3 percent of the participants receiving trimix plus sodium bicarbonate compared with 57.9 percent of those in the group treated with trimix alone.

Efficacy. The difference between the rates of improved erection in participants allocated to trimix plus sodium bicarbonate versus trimix alone was not statistically significant (78.9 percent versus 68.4 percent; RD 11 percent, 95 percent CI:-17.0–38.0). ^283^

Vasoactive intestinal peptide (VIP) plus phentolamine versus placebo. Two trials compared the efficacy and harms of vasoactive intestinal peptide (VIP) plus phentolamine versus placebo. ^260^

Harms. Compared with participants receiving placebo, those randomized to VIP plus phentolamine reported more frequent bruising (12.3 percent versus 43.1 percent), bleeding at injection site (5.1 percent versus 20.5 percent) urethral bleeding (2.6 percent versus 12.3 percent), flushing (13.3 percent versus 74.4 percent), palpitation (0 percent versus 7.7 percent), and tachycardia (0.5 percent versus 5.1 percent).

The participants in the placebo group reported bleeding at the injection site. There was no statistically significant difference between the treatment groups with respect to pain during injection (4.6 percent versus 8.2 percent), priapism (0.5 percent versus 0 percent), or headache (3.6 percent versus 1.5 percent).

Efficacy. Three hundred and four men with ED were screened for response to in-clinic or home administration of 25μg VIP plus either 1mg or 2 mg of phentolamine.

Based on the phentolamine dose to which responses were observed, 240 participants were randomized in a crossover design to active treatment versus placebo. Efficacy results were reported only for the 172 men who received at least one dose of active drug and placebo.

Seventy-two percent of injections in men allocated to VIP plus 1 mg phentolamine produced grade 3 erections (suitable for sexual intercourse) versus 13 percent in men allocated to placebo (p <0.001). The proportions of participants with grade three erections in VIP plus 2 mg phentolamine and placebo groups were 65 and 16 percent, respectively (p < 0.001)

Tables 13–15 illustrate the results presented in this section.

Table 15 Subcutaneous Injection: Improvement in Erections

Study / Type of Patients | Outcome Definition | Treatment Group% (n/N) | Control Group % (n/N) | Relative risk (RR) [95% CI] or p value
Melanotan II vs. Placebo
Wessells 2000 Psychogenic: 10 patients Physiologic: 10 patients Analysis: 10 patients with physiologic ED | Subject reported “subjectively apparent erections” on at least one of two injections Subjective erectile activity | 85.0 (17/20) 69.2 (27/39) Based on number of injections | NR 2.4 (1/41) Based on number of injections | - -
Subject reported “subjectively apparent erections” on at least one of two injections Subjective erectile activity | 90.0 (9/10) 63.2 (12/19) Based on number of injections | 10.0 (1/10) 4.8 (1/21) Based on number of injections | 9.00 [1.39–58.44] -
PT-141 (cyclic heptapeptide melanocortin analog) vs. Placebo
Rosen 2004 25 patients with moderate-severe ED with inadequate response to sildenafil. | NR NR NR

### Quantitative Synthesis

There was a large degree of clinical heterogeneity in the potentially eligible IC trials with regard to patient characteristics (e.g. proportion with psychogenic versus physiologic ED, exclusion of nonresponders during screening phase), interventions (e.g. number, dose, and duration of treatment), and assessed outcomes (see Outcomes section above). Therefore, meta-analyses were not performed.

## Injection Treatments - Subcutaneous Injections

### Literature Search

Three trials (four publications) ^295^ – ^298^ were identified and included in the review. One trial was reported in two publications. ^295,^ ^296^

### Overview of Trials

All three studies used a crossover design. (Evidence Table F-7, Appendix F)

### Populations

In these studies, ED etiology was primarily of psychogenic (69 percent) origin. Obesity, hypertension, and hypercholesterolemia were the most commonly reported underlying diseases. Mean duration of ED in one trial was 8 years.

### Interventions

The evaluated SC injection treatments were Melanotan II, ^295^ PT-141 (cyclic heptapeptide melanocortin analog) (n=25), ^298^ and apomorphine (n=12). ^297^ In all studies, SC therapy was administered in a clinic and subjects were monitored or kept under observation from 30 minutes up to 24 hours.

### Study Quality and Reporting

None of the studies reported the source of pharmaceutical funding. None of the trials reported methods of allocation concealment. Study withdrawals, drop-outs or participants lost to followup were reported in all trials. All trials were double-blind. All trials received a Jadad score of 3 (Evidence Table F-6, Appendix F).

### Outcomes

Three eligible studies assessed clinical efficacy (e.g. improvement in erections) and harms. (Tables 15 and 16)

Table 16 Subcutaneous Injection: Patients with Adverse Events

Study | Adverse event | Treatment Group % (n/N) | Control Group % (n/N) | Absolute risk difference (%) [95% CI]
Melanotan II vs. Placebo
Wessells 2000 Psychogenic and physiologic ED subgroups combined Analysis of the 10 patients with physiologic ED | Nausea (any) Nausea (severe) Yawning/stretching (any) Yawning/stretching (severe) Nausea (any) Nausea (severe) Yawning/stretching (any) Yawning/stretching (severe) | Number of injections 38.5 (15/39) 15.4 (6/39) 56.4 (22/39) 7.7 (3/39) 42.1 (8/19) 21.1 (4/19) 42.1 (8/19) 15.8 (3/19) | Number of injections 9.8 (4/41) 2.4 (1/41) 12.2 (5/41) 0 (0/41) 9.5 (2/21) 0 (0/21) 0 (0/21) 0 (0/21) | NA
PT-141 (cyclic heptapeptide melanocortin analog) vs. Placebo
Rosen 2004 AE > 5% in both treatment arms | Nausea | 24.0 (6/25) 4 mg 36.4 (8/22) 6 mg | 0 (0/24) | -
Rosen 2004 AE > 5% in both treatment arms
Rosen 2004 AE > 5% in both treatment arms | Headache | 36.0 (9/25) 4 mg 27.3 (6/22) 6 mg | 0 (0/24) | -
Vomiting | 8.0 (2/25) 4 mg 9.1 (2/22) 6 mg | 0 (0/24) | -
Diaphoresis | 8 (2/25) 4 mg 9.1 (2/22) 6 mg | 0 (0/24) | -
| Exacerbation of hypertension | 9.1 (2/22) 4 mg | 0 (0/24) | -
Apomorphine vs. Placebo
Segraves 1991 | Eight of 12 patients reported adverse events: yawning, drowsiness and nausea. Two patients had severe nausea and hypotension

### Qualitative Synthesis

Melanotan II versus placebo. One small trial enrolling 20 subjects, 10 men with psychogenic ED and 10 men with organic ED, compared the efficacy and harms of Melanotan II (SC) to placebo ^295^ . Melanotan II was administered by the investigator in doses between 0.025 mg/kg and 0.157 mg/kg in a double blind, placebo-controlled fashion. Subjects were monitored by RigiScan in the clinic and at home for a total of 6 hours.

Harms. Men administered Melanotan II reported an increased frequency of nausea (38.5 percent versus 9.8 percent), yawning and stretching (56.4 percent versus 12.2 percent). ^295^

Efficacy. 17 of the 20 subjects administered Melanotan II reported a “subjectively apparent erection” on at least one of two injections of Melanotan II. The number of subjects with improved erections following administration of placebo was not reported. Overall, erectile activity (based on RigiScan activity) was reported in 69 percent (27/39) of Melanotan II injections compared with 2 percent (1/41) of placebo injections. In a subgroup analysis of the 10 subjects with organic ED, nine men treated with Melanotan II reported a “subjectively apparent erection” versus one placebo treated subject ^296^ . Erectile activity was reported in 63 percent (12/19) of Melanotan II injections compared with 2 percent (1/21) of placebo injections.

PT-141 versus placebo. One small trial that enrolled 25 subjects with moderate to severe ED who had an inadequate response to sildenafil compared the efficacy and harms of PT-141 (SC) to placebo ^298^ . PT-141 was administered in doses of 4 or 6 mg, utilizing a placebo-controlled three-way crossover design ^298^ . Patients were kept under observation until 24 hours after the dose administration.

Harms. Men who were administered PT-141 reported an increased frequency of nausea (4 mg: 24 percent versus 6 mg: 36 percent versus placebo: 0 percent) and headache (4 mg: 36 percent versus 6 mg: 27 percent versus placebo: 0 percent) compared with placebo.

Efficacy. Clinically and statistically significant erectile response (assessed by RigiScan) in the presence of visual sexual stimulation was observed following the administration of single dose of 4 or 6 mg PT-141, relative to placebo. A greater than two-fold increase in the duration of base rigidity ≥ 60 percent, compared with placebo, was reported in 82 percent of subjects receiving the 4 mg dose and 84 percent of patients receiving the 6 mg dose.

Apomorphine versus placebo. One small trial enrolling 12 subjects with coital erectile failure of at least 6 months compared apomorphine (SC) to placebo. ^297^

Harms. Eight subjects reported side effects, including yawning, drowsiness and nausea. Two participants experienced extreme nausea and hypotension, with one transiently losing consciousness after the 1.0 mg apomorphine dose.

Efficacy. Eleven out of the 12 subjects exceeded a change of 1cm in circumference after injection).

### Quantitative Synthesis

No meta-analysis was performed due to the clinical heterogeneity with regard to intervention types.

## Intra-urethral Suppositories

### Literature Search

Seven RCTs (in seven publications) were eligible and were included in the review. ^299^ – ^305^

### Overview of Trials

Of the seven trials, ^299^ – ^305^ one reported only physiologic outcomes (timing and degree of penile rigidity as measured by RigiScan) and no harms data. ^305^ Therefore, the remaining six trials are described in more detail in this section. Of five studies, four assessed clinically relevant efficacy outcome such as home sexual intercourse success ^299,^ ^300,^ ^302,^ ^304^ and one trial reported on whether in-clinic erections were judged sufficient for intercourse. Of these six trials, ^299^ – ^304^ two were cross-over design (n=345; range: 111–234 participants) and four were parallel design (n=1726, range: 60–996 participants). No studies assessed therapies beyond 12 weeks. (Evidence Table F-7, Appendix F)

### Populations

Among the six trials reporting clinical efficacy and/or harms data, the mean age of the subjects was 60.4 years (n=6 trials reporting). Racial characteristics were reported in only one trial. ED etiology was of physiologic origin in the four studies reporting. Vascular disease and diabetes were the most commonly reported underlying diseases. Mean duration of ED was approximately 4 years. In four trials reporting, 56 percent of men reported previous treatment for ED. No trials reported smoking status and body weight (e.g. body mass index), both risk factors of ED.

### Interventions

IU treatment interventions evaluated in eligible trials were alprostadil, prazosin, and the combination of the two agents.

Among alprostadil interventions, one 3 month trial of IU alprostadil utilized a fixed dose of 1000μg. ^301^ Three trials utilized fixed doses of alprostadil from 125 to 1000μg administered at home based on each subject's response to various doses or a dose titration. ^300,^ ^302,^ ^304^ The home treatment phases of these trials were 3 weeks and 3 months, ^302,^ ^304^ respectively. In another trial, subjects received single in-clinic administrations of two of four alprostadil doses (125, 250, 500 and 1000μg) over a 2 to 4 week period. ^303^ In a sixth trial, subjects started at either 250 or 500μg alprostadil for 4 weeks with subsequent dose titration so that final dose at 12 weeks ranged from 125 to 1000μg. ^299^ Pubic bands were allowed as optional adjunct therapies in two trials. ^299,^ ^300^

In one trial that evaluated a prazosin intervention, subjects received single in-clinic administrations of two of four prazosin doses (250, 500, 1000 and 2000μg) over 2 – 4 week period. ^303^

Finally, in the single trial that evaluated a combined alprostadil/prazosin intervention, subjects received single in-clinic administrations of two of nine possible IU alprostadil/prazosin dose combinations over a 2 to 4 week period. ^303^

### Study Quality and Reporting

Information on pharmaceutical funding was reported to have been provided for five ^299,^ ^300,^ ^302^ – ^304^ of the six trials. One trial ^301^ did not report a funding source. None of the trials reported methods of allocation concealment. Participant withdrawals, drop-outs or lost to followup were reported in all trials and ranged from 7 percent to 42 percent. The majority of the trials were considered to be of low quality as assessed by the Jadad scale. Only one of the six trials received a Jadad score of 3. The remaining trials received a score of 2 or less. (Table C-1, Appendix C)

### Outcomes

Both clinical efficacy (e.g. sexual intercourse success, improvement in erections) and harms (e.g. penile pain) outcomes were assessed in all six trials. ^299^ – ^304^ More commonly reported were quality of erections achieved at home, without regard to whether the patient was able to achieve successful sexual intercourse (“improvement” in erections, “full response,” full erection,” or “grade 4 or 5 erections”). All six trials reported data on penile or urogenital pain and three trials reported results on prolonged erections or priapism/fibrosis.

### Qualitative Synthesis

Summary of qualitative synthesis for this section in presented also in Tables 17–19.

Table 17 Intra-urethral Treatment: Sexual Intercourse

Study | ED Etiology | Outcome | Treatment Group % (n/N) | Control Group % (n/N) | Relative Risk [95% CI]
Alprostadil vs. Placebo. Patients randomized included only men who had a maximal penile response (Grade of 4 or 5 on the Erection Assessment Scale) with at least one dose of alprostadil
Padma-Nathan* 1997 | Physiologic: 100% | Total successful attempts (diary self-report) after 3 months | 50.4 (2485/4933) | 10.4 (454/4346) | 4.82[4.40–28.00]
Williams* 1998 | Physiologic: 100% | Total successful attempts (diary self-report) after 3 months | 51.1 (390/763) | 7.5 (46/611) | 6.79[5.10–9.04]
I
Padma-Nathan* 1997 | Physiologic: 100% | Total successful attempts for men who had successful intercourse at least once (diary self-report) after 3 months | 69.2 (2485/3593) | 10.4 (454/4346) | 6.62[6.05–7.24]
Williams* 1998 | Physiologic: 100% | Total successful attempts for men who had successful intercourse at least once (diary self-report) after 3 months | 61.4 (390/635) | 7.5 (46/611) | 8.16[6.14–10.84]
II
Padma-Nathan* 1997 | Physiologic: 100% | Total successful intercourse attempts or orgasm (diary self-report) after 3 months | 56.3 (2770/4921) | 15.4 (668/4331) | 3.65[3.39–3.93]
Padma-Nathan* 1997 | Physiologic: 100% | Patients reporting successful intercourse at least once (diary self-report) after 3 months | 61.6 (299/485) All men randomized | 18.2 (93/511) All men randomized | 3.39[2.78–4.12]
Williams* 1998 | Physiologic: 100% | Patients reporting successful intercourse at least once (diary self-report) after 3 months | 59.0 (46/78) All men randomized | 9.9 (8/81) All men randomized | 5.97[3.01–11.83]
III
Padma-Nathan* 1997 | Physiologic: 100% | Patients reporting successful intercourse at least once (diary self-report) after 3 months | 64.9 (299/461) Men with ≥ 1 administration | 18.6 (93/500) Men with ≥ 1 administration | 3.49[2.87–4.24]
Williams* 1998 | Physiologic: 100% | Patients reporting successful intercourse at least once (diary self-report) after 3 months | 68.7 (46/67) Men with ≥ 1 administration | 7.5 (8/73) Men with ≥ 1 administration | 6.26[3.19–12.29]
Alprostadil (IU) vs. Alprostadil (ICI)
Shokeir 1999 | Physiologic: 100% | Total successful attempts (diary self-report) after 3 months | 55.0 (198/360) | 85.1 (206/242) | 0.65[0.58–0.72]
Shokeir 1999 | Physiologic: 100% | Patients reporting successful intercourse at least once | 53.3 (16/30) | 86.7 (26/30) | 0.62[0.43–0.88]
Alprostadil (titrated; starting dose 250 μg),) vs. Alprostadil (titrated; starting dose 500 μg)
Ekman 2000 | NR Vascular: 43%–47%Diabetes: 21% Psychogenic: 7%–12% | Patients reporting successful intercourse at least once | 68.1 (113/166) | | -

Table 18 Intra-urethral Treatment: Improvement in Erections*

Study | ED etiology | Treatment Group % (n/N) | Control Group % (n/N) | Relative Risk [95% CI]
Alprostadil vs. Placebo
Padma-Nathan 1997 | Physiologic: 100% | 65.9 (996/1511)** Dosing phase | NA | -
Williams 1998 | Physiologic: 100% | 63.9 (159/249)** Dosing phase | NA | -
Alprostadil vs. Prazosin (IU)
Peterson 1998 | Physiologic: 100% | Range for % response (dose) 14.1 (125 mcg) – 31.0 (500 mcg) | % Response (dose) 3.0 (2000 mcg) | -
Alprostadil + Prazosin (IU) vs. Placebo
Peterson 1998 | Physiologic: 100% | Range for % response (Alprostadil dose/Prazosin dose) 30.4 (125 mcg/500 mcg) – 35.7 (500 mcg/2000 mcg) | 0.4 | -
Alprostadil (IU) vs. Alprostadil (ICI)
Shabsigh 2000 | NR | 21.1 (20/95) In-office titration phase, Positive buckling test 61.8 (42/68) At-home phase, ≥ 1 erection sufficient for intercourse | 61.1 (58/95) In-office titration phase, Positive buckling test 92.6 (63/68) At-home phase, ≥ 1 erection sufficient for intercourse | 0.34 [0.23–0.53] 0.67 [0.55–0.81]
Shokeir 1999 | Physiologic: 100% | 60.0 (18/30) | 90.0 (27/30) | 0.67 [0.49–0.91]
Alprostadil (starting dose 250 μg) vs. Alprostadil (starting dose 500 μg)
Ekman 2000 | NR Vascular: 43%–47% Diabetes: 21% Psychogenic: 7%–12% | 73.5 (122/166) | | -
Prazosin (IU) vs. Placebo
Peterson 1998 | Physiologic: 100% | % Response (dose) 3.0 (2000 mcg) | % Response 0.4 | -

* Defined as full erection or “positive response,” Grade 4/5 erections, erections sufficient for intercourse, or Rigiscan assessment ≥ 70% rigidity base or tip lasting ≥ 10 minutes

** Patients achieving an adequate erectile response were then randomized in the double blind placebo controlled home phase

Table 19 Intra-urethral Treatment: Patients with Adverse Events

Study | Adverse Event | Treatment Group % (n/N) | Control Group % (n/N) | Absolute Risk Difference [95% CI]
Alprostadil vs. Placebo
Padma-Nathan 1997 | Penile pain | 32.8 (159/485) | 3.3 (17/511) | 29.0 [25.0–34.0]
Williams 1998 | Penile pain | 5.0 (4/78) | 1.2 (1/81) | 4.0 [-2.0, 9.0]
Padma-Nathan 1997 | Minor urethral trauma | 5.2 (25/485) | <1.0 (5/511) | 4.0 [2.0–6.0]
Williams 1998 | Minor urethral trauma | 1.3 (1/78) | 1.2 (1/81) | 0.0 [-2.0, 7.0]
Padma-Nathan 1997 | Dizziness | 1.9 (9/485) | <1.0 (1/511) | 2.0 [0.0–3.0]
Williams 1998 | Dizziness | 2.6 (2/78) | 0 (0/81) | -
Padma-Nathan 1997 | Prolonged erection | 0 | 0 | -
Williams 1998 | Prolonged erection | 1.3 (1/78) | 0 | -
Williams 1998 | Urogenital pain/burning | 6.4 (5/78) | 0 | -
Padma-Nathan 1997 | Other events: Priapism or fibrosis Urinary tract infection | 0 <1 (1/485) | 0 <1 (3/511) | - -
Williams 1998 | Testicular pain Priapism or fibrosis Urinary tract infection | 2.6 (2/78) 0 0 | 0 0 0 | - - -
Alprostadil vs. Prazosin (IU)
Peterson 1998 | Penile pain Urethral pain Testicular pain Dizziness Hypotension Priapism or fibrosis There were 12 cases of minor urethral bleeding and 2 cases of prolonged erections (no treatment arms reported). | Dose range 125–1000 mcg % Range 17.0–23.6 1.0–9.1 2.0–4.4 0–5.5 1.0–3.6 0 0 | Dose range 250–2000 mcg % Range 0.7 –5.5 0–2.1 0–1.4 0–0.7 0–1.8 0 0 | - - - - - -
Alprostadil + Prazosin (IU) vs. Placebo
Peterson 1998 | Penile pain Urethral pain Testicular pain Dizziness Hypotension Priapism or fibrosis | Alprostdil (dose range: 125–1000 mcg) + Prazosin (dose range: 250–2000 mcg) % Range 17.0–31.6 1.9–13.5 1.8–6.8 0–11.5 0–14.0 0 | 1.7 1.7 0.4 0 0 0 | - - - - - -
Alprostadil (IU) vs. Alprostadil (ICI)
Shabsigh 2000 | Patients with ≥ 1 AE Penile pain Prolonged erections Local bleeding | 55.8 (53/95) Office 57.4 (39/68) Home 30.5 (29/95) Office 25.0 (17/68) Home 0 Office 0 Home 4.2 (4/95) Office 2.9 (2/68) Home | 30.5 (29/95) Office 52.9 (36/68) Home 20 (19/95) Office 33.8 (23/68) Home 2.1 (2/95) Office 2.9 (2/68) Home 1.1 (1/95) Office 1.5 (1/68) Home | 25.0 [12.0–39.0] 4.0 [-12.0, 21.0] 11.0 [-2.0, 23.0] -9.0 [-24.0, 6.0] - - 3.0 [-1.0, 8.0] 1.0 [-3.0, 6.0]
Shokeir 1999 | Urogenital pain Urethral bleeding Dizziness | 6.7 (2/30) 3.3 (1/30) 6.7 (2/30) | 46.7 (14/30) 0 0 | -40.0 [-20.0, -60.0] - -
Alprostadil (starting dose 250 μg) vs. Alprostadil (starting dose 500 μg)
Ekman 2000 | Pain | 30.1 (50/166) 2% rated severe | | -
Prazosin vs. Placebo
Peterson 1998 | Penile pain Urethral pain Testicular pain Dizziness Hypotension Priapism or fibrosis | % Range 0.7–5.5 0–2.1 0–1.0 0–1.0 0–2.0 0 | 1.7 | -

Alprostadil versus placebo. Three trials compared the efficacy and harms of IU alprostadil to placebo. ^302^ – ^304^

Harms. In the first trial, compared with men in placebo group, alprostadil-treated men had an increased frequency of penile pain (3.3 percent versus 32.8 percent) and minor urethral trauma (1.0 percent versus 5.2 percent). ^304^ Urinary tract infection occurred in fewer than 1 percent of participants in both groups. No cases of prolonged erection, priapism or fibrosis were observed in either treatment group.

In the second trial, men randomized to IU alprostadil reported an increased frequency of urogenital burning (6.4 percent versus 0 percent), but statistically nonsignificant increase in risk of penile pain (5.1 percent versus 1.2 percent), dizziness (2.6 percent versus 0 percent), prolonged erection (1.3 percent versus 0 percent), and testicular pain (2.6 percent versus 0 percent). ^302^

Minor urethral trauma was reported by 1.3 and 1.2 percent of men allocated to IU alprostadil and placebo, respectively.

There were no cases of priapism or fibrosis, or urinary tract infection in either treatment group.

In the third trial, penile pain was reported by 1.7, 23.6, 20.5, 20.9 and 17.0 percent of men allocated to placebo, 1000μg, 500μg, 250μg, and 125μg IU alprostadil, respectively, ^303^ The corresponding proportions for reporting testicular pain were: 0.4, 1.8, 4.4, 4.4, and 2.0 percent.

Urethral pain was reported by 1.7, 9.1, 8.0, 5.1, and 1.0 percent of the men allocated to placebo, 1000μg, 500μg, 250μg, and 125μg IU alprostadil, respectively.

Efficacy. Men randomized to IU alprostadil reported that 50.4 percent of their sexual intercourse attempts during the 3 month treatment period were successful versus 10.1 percent for men allocated to placebo. Sixty-two percent of men allocated to IU alprostadil reported at least one successful sexual intercourse attempt during the study period versus 18.2 percent of men allocated to placebo.

In the second trial, men randomized to IU alprostadil reported that 51.1 percent of their sexual intercourse attempts during the 3 month treatment period were successful versus 7.5 percent for men allocated to placebo. In the third trial, ^303^ 31 percent of men reported erections sufficient for intercourse (grade 4 or 5) with 500μg IU alprostadil versus 14.1 percent of the men treated with 125μg IU alprostadil. Results were not provided for 250μg and 1000μg alprostadil doses.

Alprostadil (250μg) versus alprostadil (starting dose: 500μg). One trial ^299^ compared the efficacy and harms of initiating IU alprostadil treatment at doses of 250μg and 500μg.

Harms. In the 4 weeks prior to IU alprostadil dose titration, 14.5 percent of men allocated to an initial dose of 250μg reported penile pain versus 27.7 percent of those allocated to an initial dose of 500μg (p <0.05). During this period, there was no difference between treatment groups for urethral pain (250μg: 1.2 percent versus 500μg: 2.4 percent) or hypotension/dizziness (250μg: 2.4 percent versus 500μg : 3.6 percent).

Efficacy. Seventy-seven percent of men allocated to an initial dose of 250μg versus 69 percent of those allocated to an initial dose of 500μg elected to increase their dose at 4 weeks. Pooled clinical efficacy results were presented for treatment groups, namely the proportion of men during the study period with at least one successful sexual intercourse attempt (68.1 percent) and the proportion with erections sufficient for intercourse (grade 4 or 5) (73.5 percent). ^299^

Alprostadil (IU) versus alprostadil (IC). Two trials compared the efficacy and harms of IU alprostadil versus IC alprostadil. ^300,^ ^301^

Harms. In the first trial, men allocated to IU alprostadil were less likely to report urogenital pain than those allocated to IC alprostadil (6.7 percent versus 46.7 percent) with statistically nonsignificant differences between the treatment groups for urethral bleeding (3.3 percent versus 0 percent) or dizziness (6.7 percent versus 0 percent). ^301^ In the second trial, there was no statistically significant difference between the two treatment groups with regard to penile pain (25.0 percent versus 33.8 percent), prolonged erections (0 versus 2.9 percent), or local bleeding (2.9 versus 1.5 percent). ^300^

Efficacy. In one trial, men randomized to IU alprostadil reported 55.0 percent successful intercourse attempts versus 85.1 percent for those allocated to IC alprostadil. ^301^ Furthermore, 53.3 percent of men allocated to IU alprostadil reported at least one successful sexual intercourse attempt during the study period versus 86.7 percent of men allocated to IC alprostadil. In the second 3-week trial, 61.8 percent of men randomized to IU alprostadil reported at least one erection sufficient for intercourse during at home use versus 92.6 percent of those allocated to IC alprostadil. ^300^

Alprostadil (IU) versus prazosin (IU). One trial compared the efficacy and harms of IU alprostadil versus IU prazosin. ^303^

Harms. Penile pain was reported by 23.6, 20.5, 20.9 and 17.0 percent of men allocated to 1000μg, 500μg, 250μg, and 125μg IU alprostadil, respectively versus 5.5, 0.7, 1.4 and 1.1 percent of men allocated to 2000μg, 1000μg, 500μg, and 250μg IU prazosin, respectively. ^303^ Urethral pain was reported by 9.1, 8.0, 5.1, and 1.0 percent of men allocated to 1000μg, 500μg, 250μg, and 125μg IU alprostadil, respectively versus 0, 2.0, 2.0, and 2.1 percent of men allocated to 2000μg, 1000μg, 500μg, and 250μg IU prazosin, respectively.

Efficacy. In this trial, each of 234 participants received single administrations of two of four potential alprostadil doses (125, 250, 500 and 1000μg) and two of four potential prazosin doses (250, 500, 1000 and 2000μg). Thirty-one percent of men with 500μg IU alprostadil reported erections sufficient for intercourse (grade 4 or 5) versus 14.1 percent with 125μg IU alprostadil versus 3 percent of men with 2000μg prazosin. Results were not provided for the 250μg and 1000 μg alprostadil doses or for the 250μg, 500μg, and 1000μg prazosin doses.

Prazosin (IU) versus placebo. One trial compared the efficacy and harms of prazosin versus placebo. ^303^

Harms. Penile pain was reported by 5.5, 0.7, 1.4 and 1.1 percent of men allocated to 2000, 1000, 500, and 250μg IU prazosin, respectively, versus 1.7 percent of those allocated to placebo. Urethral pain was reported by 0, 2.0, 2.0, and 2.1 percent of men allocated to 2000, 1000, 500, and 250μg IU prazosin, respectively, versus 1.7 percent of those allocated to placebo.

Efficacy. In this trial, 3 percent of men assigned to 2000μg IU prazosin reported erections sufficient for intercourse versus 0.4 percent of those assigned to treatment with placebo. Results were not provided for the 250, 500, and 1000μg prazosin doses, though it was stated that 2000μg was the most efficacious prazosin dose.

Alprostadil (IU) plus IU prazosin versus IU alprostadil versus IU prazosin versus placebo. One trial compared the efficacy and harms of IU alprostadil plus IU prazosin versus IU alprostadil versus IU prazosin versus placebo. ^303^ All combinations of IU alprostadil plus IU prazosin appeared to improve erections more than IU prazosin or placebo.

Harms. The proportions of patients with penile pain among those allocated to various alprostadil/prazosin combinations were: 23.9(125μg/250μg), 23.4 (125μg/500μg), 23.4 (250μg/250μg), 17.0 (250μg /500μg), 27.3 (250μg /1000μg), 23.2 (500μg /500μg), 23.1 (500μg/1000μg), 31.6 (500μg /2000μg), and 26.9 percent (1000μg /1000μg). The proportions of patients with penile pain who were allocated to various doses of IU alprostadil were: 23.6 (1000μg), 20.5 (500μg), 20.9 (250μg), and 17.0 percent (125μg). The corresponding proportions for various doses of IU prazosin were: 5.5 (2000μg), 0.7 (1000μg), 1.4 (500μg) and 1.1 percent (250μg). Of the placebo-treated patients, 1.7 percent experienced penile pain.

The corresponding proportions of patients with urethral pain with respect to various alprostadil/prazosin combinations were: 6.5, 10.6, 8.5, 8.5, 11.4, 7.1, 1.9, 5.3, and 13.5 percent respectively. The corresponding proportions of men with urethral pain for various doses of IU alprostadil were: 9.1, 8.0, 5.1, and 1.0 percent, respectively. The proportions for various doses of IU prazosin were: 0, 2.0, 2.0, and 2.1 percent respectively. Urethral pain was experienced by 1.7 percent of the placebo-treated patients.

Efficacy. Erections sufficient for intercourse were reported by 30.4 percent of men assigned to 125/500μg alprostadil/prazosin versus 31.9 percent with 250/500μg alprostadil/prazosin, 35.7 percent with 500/2000μg alprostadil/prazosin, 31.1 percent with 500μg alprostadil, 14.1 percent with 125μg alprostadil, 3 percent with 2000μg prazosin, and 0.4 percent with placebo. Results were not provided for the other six alprostadil/prazosin combinations tested, for the 250 and 1000μg alprostadil doses, or for the 250, 500, and 1000μg prazosin doses. However, it was stated that 500/2000μg was the most efficacious alprostadil/prazosin dose, 500μg was most efficacious alprostadil dose, and 2000μg was the most efficacious prazosin dose.

### Quantitative Synthesis

There was a large degree of clinical heterogeneity among the eligible IU trials with regard to patient characteristics (e.g. inclusion/exclusion criteria), interventions (e.g. fixed or flexible dosing, dose titration, treatment duration per individual ranging from single administration to 3 months), and assessed outcomes (see Outcomes section above). Therefore, meta-analyses on these studies were not performed.

## Topical Treatments

### Literature Search

Twelve unique trials (11 publications) were identified as eligible for evaluating topical treatments in ED patients and were included in the review. ^144,^ ^306^ – ^315^ One publication ^306^ described and reported two distinct trials in patients with mid to moderate (trial a) and severe ED (trial b). Additional studies of topical testosterone are described in the Hormonal Treatment section.

### Overview of Trials

Of the 12 trials, five reported only physiologic efficacy outcomes, such as in-clinic assessment of degree or duration of penile rigidity. ^307^ – ^311^ The remainder of this section emphasizes results from the seven trials that assessed validated and clinically relevant efficacy outcomes such as sexual intercourse success or improvement in erections at home. ^144,^ ^306,^ ^312^ – ^315^ Of these seven trials, three used crossover and four used parallel design. None of these studies assessed therapies beyond 6 months. (Evidence Table F-8, Appendix F)

### Populations

Patient characteristics presented are based on data from all 12 unique trials. The mean age of the subjects was 59 years. Racial characteristics were reported in only three trials. The majority of the subjects were Caucasians (86 percent). ED etiology was primarily of physiologic origin (59.7 percent). Vascular disease and diabetes were the most commonly reported underlying causes of ED. Mean duration of ED was approximately 2.7 years, (three trials reporting). Only two trials reported smoking status and none of the trials reported data on obesity.

### Interventions

Topical treatments evaluated in the seven trials that reported clinical efficacy outcomes were alprostadil ^306^ , nitroglycerine; ^313,^ ^315^ aminophylline plus isosorbide dinitrate plus co-dergocrine; ^312,^ ^314^ minoxidil; ^313^ and sildenafil. ^144^

In the first two trials (studies a and b) ^306^ , the administered alprostadil doses were 50μg, 100μg, 200μg or 300μg. In one trial, 2.5 gm of 10 percent nitroglycerine ointment was applied twice daily to the penile shaft for 2 months. ^313^ In another, subjects applied a plaster to the penile shaft one hour prior to anticipated sexual activity that released 10 mg nitroglycerine per 24 hours. ^315^

In two trials, subjects received 2 gm doses of 3 percent aminophylline plus 0.25 percent isosorbide dinitrate plus 0.05 percent co-dergocrine cream, to be applied to the penile shaft and glans penis 15 minutes before anticipated sexual activity. ^312,^ ^314^

In one trial, subjects applied 1 mL of 2 percent minoxidil solution twice daily on the glans penis. ^313^

Finally, in one trial, subjects applied 0.5 gm of 1 percent sildenafil gel applied to the glans penis five minutes before expected sexual activity. Participants were followed for up to 2 weeks, though it was not clear whether or not they received more than one dose. ^144^

### Study Quality and Reporting

Sources of pharmaceutical funding was provided for four trials. The remainder of trials did not report a funding source. Treatment allocation concealment was usually unclear. One trial reported adequate allocation concealment during randomization. ^312^ . Only one trial received a total Jadad score of 4 and none received a score of 5. The remaining trials received scores of 3 or 2. (Table C-1, Appendix C)

### Outcomes

Only the seven studies ^144,^ ^306,^ ^312^ – ^315^ that assessed clinical efficacy outcomes (e.g. IIEF-EF domain scores, sexual intercourse success, improvement in erections) are described here. Of the trials reporting the clinical efficacy outcomes, only four reported results for sexual intercourse success. More commonly reported outcomes were quality of erections achieved at home.

### Qualitative Synthesis

Summary of the results presented in this section is also available in Tables 20–22

Table 20 Alprostadil (Topical Cream) vs. Placebo: Sexual Encounter Profile (SEP)

Study / Duration | | Placebo (%) | Alprostadil Topical Cream
50 μg (%) | 100 μg (%) | 200 μg (%) | 300 μg (%)
1. Rate of successful vaginal penetration/total attempts (SEP Question): Were you able to insert your penis into your partners' vagina? (yes/no)
Padma-Nathan 2003 6 weeks Patients with mild-to-moderate ED (Study a) | Number of patients | 31 | 31 | 29 | 26 | NA
Padma-Nathan 2003 6 weeks Patients with mild-to-moderate ED (Study a) | Baseline | NR | NR | NR | NR | NA
Padma-Nathan 2003 6 weeks Patients with mild-to-moderate ED (Study a) | End point success rate ± standard deviation | 55.3 ± 40.0 | 69.4 ± 34.2 | 69.1 ± 39.3 | 82.9 ± 24.6 | NA
Padma-Nathan 2003 6 weeks Patients with mild-to-moderate ED (Study a) | Mean change | NR | NR | NR | NR | NA
p value vs. placebo | NA | NS | NS | 0.01
Padma-Nathan 2003 6 weeks Patients with severe ED (study b) | Number of patients | 35 | NA | 34 | 29 | 29
Padma-Nathan 2003 6 weeks Patients with severe ED (study b) | Baseline success rate | NR | NA | NR | NR | NR
Padma-Nathan 2003 6 weeks Patients with severe ED (study b) | End point success rate ± standard deviation | 15.6 ± 17.2 | NA | 32.3 ± 18.0 | 36.2 ± 29.3 | 38.6 ± 22.8
Padma-Nathan 2003 6 weeks Patients with severe ED (study b) | Mean change | NR | NA | NR | NR | NR
p value vs. placebo | NA | NS | NS | NS

Table 21 Topical Treatment: Improvement in Erections*

Study | ED Etiology | Treatment Group % (n/N) | Control Group % (n/N) | Relative Risk [95% CI]
Alprostadil vs. Placebo
Goldstein 2001 | Vascular: 97% | 38.7 (12/31) | 6.9 (2/29) | 5.61 [1.37–22.96]
Padma-Nathan 2003 6 weeks Patients with mild-to-moderate ED (Study a) | NR | 80.2 (69/86) All doses | 54.8 (17/31) | 1.46 [1.05–2.05]
Padma-Nathan 2003 6 weeks Patients with mild-to-moderate ED (Study a) | NR | 81.0 (25/31) 50 μg | 54.8 (17/31) | 1.47 [1.02–2.11]
Padma-Nathan 2003 6 weeks Patients with mild-to-moderate ED (Study a) | NR | 69.0 (20/29) 100 μg | 54.8 (17/31) | 1.26 [0.84–1.88]
92.0 (24/26) 200 μg | 54.8 (17/31) | 1.68 [1.20–2.36]
Padma-Nathan 2003 6 weeks Patients with severe ED (study b) | NR | 71.7 (66/92) All doses | 25.7 (9/35) | 2.79 [1.57–4.97]
Padma-Nathan 2003 6 weeks Patients with severe ED (study b) | NR | 58.8 (20/34) 100 μg | 25.7 (9/35) | 2.29 [1.22–4.29]
Padma-Nathan 2003 6 weeks Patients with severe ED (study b) | NR | 75.9 (22/29) 200 μg | 25.7 (9/35) | 2.95 [1.62–5.37]
82.7 (24/29) 300 μg | 25.7 (9/35) | 3.22 [1.79–5.79]
Aminophylline + Isosorbide dinitrate + Co-dergocrine vs. Placebo,
Gomaa 1996 | Physiologic: 52.3% Psychogenic: 25% Mixed: 22.2% | 58.3 (21/36) | 8.3 (3/36) | 7.00 [2.29–21.41]
Le Roux 1999 | Physiologic: 28.6% Psychogenic: 71.4% | 3.9 (3/77 applications, 8 patients) | 5.3 (4/76 applications, 8 patients) | 0.74 [0.17–3.20]
Minoxidil vs. Nitroglycerin
Cavallini 1994 | Physiologic: 100% | 44.0 (51/116) | 20.7 (24/116) | 2.13 [1.41–3.21]
Minoxidil vs. Placebo
Cavallini 1994 | Physiologic: 100% | 44.0 (51/116) | 1.7 (2/116) | 25.5 [6.36–102.29]
Nitroglycerine plasters vs. Placebo plasters
Gramkow 1999 | Physiologic: 27.8% Psychogenic: 66.7% Mixed: 5.6% | 16.7 (3/18) | 11.1 (2/18) | 1.50 [0.28–7.93]
Topical sildenafil + Oral placebo vs. Oral sildenafil + Topical placebo,
Yonessi 2005 | Physiologic: 41.3% Psychogenic: 58.8% | 12.5 (5/40) | 70.0 (28/40) | 0.18 [0.08–0.42]

* Defined as full erection, erections sufficient for intercourse, improved erections based on Global Assessment Questionnaire, or RigiScan assessment ≥ 60% rigidity (“good to excellent effect”)

** Intention-to-treat population, defined as patients receiving ≥ one dose of study medication and ≥ one post-baseline efficacy evaluation. Of a total of 1732 patients, 83 patients (4.8%) were not evaluated

† Includes only patients from the cohort for the primary efficacy endpoint analysis, defined as (a) used ≥ three doses of study medication in conjunction with attempts at sexual intercourse between visits 2 and 4, (b) reported both baseline and end of treatment efficacy data (International Index of Erectile Function (IIEF), (c) reported a baseline score for the IIEF EF domain of ≤ 21, and (d) tolerated the test dose at visit 2

†† Based on a difficulties in maintaining an erection during intercourse scale, scored from 1 (always) to 6 (never). A score of 3 indicates difficulties 50% of the time.

Table 22 Topical Treatment: Patients with Adverse Events

Study | Adverse Event | Treatment Group % (n/N) | Control Group % (n/N) | Absolute Risk Difference [95% CI]
Alprostadil vs. Placebo
Goldstein 2001 | Patients withdrawn from therapy due to adverse events | 0/31 | 0/29 | -
Goldstein 2001 | Penile erythema | NR | | -
Mild/minor warmth or burning, tingling, and coolness | Reported by most patients after both alprostadil and placebo application | | -
Padma-Nathan 2003 6 weeks Patients with mild-to-moderate ED (Study a) | Urogenital pain | 13.2% (16/121) 12%: 50μg 15%: 100μg 13%: 200μg | 0 (0/40) NR | -
Hypotension | 5.0% (6/121) 2.0%: 50μg 3.0%: 100μg 1.0%: 200μg | 0 (0/40) NR | -
Padma-Nathan 2003 6 weeks Patients with severe ED (Study b) | Urogenital pain | 5.5% (6/109) 0%: 100μg 9.0%: 200μg 8.0%: 300μg | 0 (0/35) NR | -
Hypotension | 6.4% (7/109) 0%: 100μg 11.0%: 200μg 8.0%: 300μg | 0 (0/35) NR | -
Topical PgE1 with or without Calcium Thioglycolate or Methyl Salicylate vs. Placebo
Foldavi 1998 | Patients with ≥ 1 AE | No local AEs were observed during the study | | -
Aminophylline + Isosorbide dinitrate + Co-Dergocrine vs. Placebo,
Gomaa 1996 | Patients with ≥ 1 AE | No Patient reported prolonged erection/priapism, clinically significant cardiovascular events or complaints from patients' partners | | -
Le Roux 1999 | No AE reported | - | - | -
Nitroglycerin vs. Placebo
Cavallini 1994 | Patients with ≥ 1 AE | 44.8 (52/116) | 0 (0/116) | 45.0 [36.0–54.0]
Cavallini 1994 | Burning at application site | 12.6 (14/116) | 0 (0/116) | 12.0 [6.0–18.0]
Hypotension | 10.3 (12/116) | 0 (0/116) | 10.0 [5.0–16.0]
Cavallini 1991 | Patients with ≥ 1 AE (burning at application site, headache, hypotension) | 45.5 (15/33) | 0 (0/33) | -
Nitroglycerin vs. Minoxidil
Cavallini 1994 | Patients with ≥ 1 adverse event | 44.8 (52/116) | 6.0 (7/116) | 39.0 [29.0–49.0]
Cavallini 1994 | Burning at application site | 12.6 (14/116) | 6.0 (7/116) | 6.0 [-1.0, 13.0]
Hypotension | 10.3 (12/116) | 0 (0/116) | -
Minoxidil vs. Placebo
Cavallini 1994 | Patients with ≥ 1 AE | 6.0 (7/116) | 0 (0/116) | -
Cavallini 1994 | Burning at application site | 6.0 (7/116) | 0 (0/116) | -
Hypotension | 0 (0/116) | 0 (0/116) | -
Cavallini 1991 | Patients with ≥ 1 adverse event (burning at application site) | 6.1 (2/33) | 0 (0/33) | -
Nitroglycerine vs. Placebo
Gramkow 1999 | Patients withdrawn from therapy due to adverse events | 1/18 due to severe pain from plaster | 0/18 | -
Gramkow 1999 | Headache (mild) | 35.4 (35/99) plasters used | 1.1 (1/92) plasters used | 34.0 [25.0–44.0]
Smarting pain | 23.2 (23/99) plasters used | 1.1 (1/92) plasters used | 22.0 [14.0–31.0]
Claes 1992 | Patients withdrawn from therapy due to AEs | 4 patients due to headache (unclear if due to active treatment) | | -
Topical sildenafil + Oral Placebo vs. Oral Sildenafil + Topical Placebo
Yonessi 2005 | Headache | 10.0 (4/40) | 5.0 (2/40) 1 case each of dyspepsia and visual disturbance | 5.0 [-6.0, 16.0]
Intranasal Cyclic Heptapeptide Melanocortin Analog (PT-141) vs. Placebo
Diamond 2004 | Flushing | 16.7 (8/48) | 4.2 (1/24) | 13.0 [-1.0, 26.0]
Diamond 2004 | Nausea | 10.4 (5/48) | 0 (0/24) | -
Feeling hot | 4.2 (2/48) | 4.2 (1/24) | -

Topical Alprostadil versus Placebo.

Harms. According to data reported from one trial (study a), ^306^ in patients with mild to moderate ED, any adverse events were more frequent in those allocated to alprostadil given at 50μg (66.7 percent), 100μg (66.7 percent) or 200μg (77.5 percent) versus placebo (52.5 percent) the corresponding proportions in the second trial with patients with severe ED (study b) for alprostadil given at 100μg, 200μg, 300μg versus placebo were 30, 60, and 51 versus 11 percent respectively. The incidence of adverse events and withdrawals due to adverse events in both patient populations conformed a dose-response trend and that urogenital pain and hypotension occurred numerically more frequently with alprostadil than with placebo.

Efficacy. The success rate of vaginal penetration was assessed in two trials of mild to moderate (study a) and severe patients (study b). ^306^ Within men with severe ED (study b), compared with those allocated to placebo, who reported a 15.6 percent success rate of vaginal penetration at study end, success rates for men allocated to alprostadil were 32.3 percent for 100μg, 36.2 percent for 200μg, and 38.6 percent for 300μg, with none of the between group differences reaching statistical significance. In men with mild to moderate ED (study a), men allocated to placebo reported a 55.3 percent success rate, while the success rates in alprostadi groups were 69.4 percent for 50μg (p > 0.05 versus placebo), 69.1 percent for 100μg (p>0.05 versus placebo), and 82.9 percent for 200μg (p = 0.01 versus placebo).

Topical Nitroglycerine versus Placebo. Two trials compared the efficacy and harms of nitroglycerine to placebo. ^313,^ ^315^

Harms. In the first trial, men allocated to nitroglycerine ointment compared with placebo reported more adverse events (frequent burning at the application site: 12.6 versus 0 percent; hypotension: 10.3 versus 0 percent). ^313^ In the second trial, men allocated to nitroglycerine plaster had more frequent headache (35.4 versus 1.1 percent) and smarting pain (23.2 versus 1.1 percent) compared with placebo. ^315^ In addition, 6 percent of men allocated to nitroglycerine withdrew from therapy due to adverse events (severe pain) versus 0 percent of placebo subjects.

Efficacy. In one trial of men with physiologic ED (n=132 randomized), 20.7 percent of those allocated to 2.5 g nitroglycerine ointment twice daily over 2 months reported improved erections versus 1.7 percent of those allocated to placebo. ^313^ In a second trial, men with predominately psychogenic ED and at least partial in-clinic erectile response to intracavernosal papaverine (n=19) were allocated to 10 mg nitroglycerine plaster administered at least one hour prior to anticipated sexual activity for up to 6 doses not more often than once daily versus placebo plaster. Among those in the nitroglycerine plaster group, 16.7 percent reported improved erections versus 11.1 percent of those in the placebo plaster group. ^315^

Topical Nitroglycerine versus Minoxidil. One trial (n=132 participants) compared the efficacy and harms of nitroglycerine ointment to minoxidil. ^313^

Harms. Men assigned to received nitroglycerine ointment group reported more frequent side effects than did men in the minoxidil group, including more frequent burning at the application site (12.6 versus 6 percent) and hypotension (10.3 versus 0 percent). ^313^

Efficacy. Among men in the nitroglycerine ointment group, 20.7 percent reported improved erections versus 44.0 percent of those in the minoxidil group.

Topica Aminophylline plus Isosorbide dinitrate plus Co-dergocrine versus Placebo. Two crossover trials compared the efficacy and harms of Aminophylline plus Isosorbide dinitrate plus Co-dergocrine versus placebo. ^312,^ ^314^ In the first trial (n=36), men with predominately physiologic ED were assigned to receive 2 gm of 3 percent aminophylline plus 0.25 percent isosorbide dinitrate plus 0.05 percent co-dergocrine mesylate taken once during a 7 day period versus placebo. ^314^ In the second trial (n=14), men with predominately psychogenic ED who previously responded to IC injections were allocated to 2 ml doses of 3 percent aminophylline plus 0.25 percent isosorbide dinitrate plus 0.05 percent co-dergocrine mesylate or placebo. ^312^

Harms. None of the patients had prolonged erection or priapism, clinically significant cardiovascular adverse events (such as postural dizziness), headache, or pain at site of application. ^314^ The other trial did not report any data on harms. ^312^

Efficacy. In the first trial, among men assigned to active treatment, 58.3 percent reported erection sufficient for successful intercourse versus 8.3 percent of those allocated to placebo. ^314^ In the second trial, men assigned to the active treatment reported that they experienced erections adequate for intercourse after 3.9 percent of treatment applications versus after 5.3 percent of placebo applications. All successful applications for both the active treatment and placebo groups occurred in a single participant. ^312^

Minoxidil versus Placebo. One crossover trial (n=132) compared the efficacy and harms of minoxidil to placebo. ^313^

Harms. Compared with placebo, men allocated to minoxidil reported more frequent burning at the application site (6 versus 0 percent). No hypotension was reported by either the minoxidil or placebo-treated participants.

Efficacy. Among men allocated to minoxidil, 44.0 percent reported improved erections versus 1.7 percent of those allocated to placebo.

Topical Sildenafil versus Oral Sildenafil. One trial (n=80) compared the efficacy and harms of topical sildenafil to oral sildenafil. ^144^

Harms. In men assigned to receive topical sildenafil, four (10 percent) reported mild headache. In those assigned to receive oral sildenafil, two participants (5 percent) developed severe headache, one participant (3 percent) reported disturbed visual function, and one participant (3 percent) experienced severe dyspepsia.

Efficacy. Among men assigned to the topical sildenafil plus oral placebo group, 12.5 percent reported improved erections versus 70.0 percent for men assigned to the oral sildenafil plus topical placebo group.

### Quantitative Synthesis

No meta-analysis could be performed because of substantial degree of clinical heterogeneity across the trials with regard to patient characteristics, interventions, and the assessed outcomes.

## Hormonal Treatments

### Literature Search

There were 20 unique studies (in 20 publications) that met eligibility criteria. ^5,^ ^77,^ ^145,^ ^170,^ ^231,^ ^316^ – ^330^ One study was reported in two publications ^317,^ ^318^ and will be referred as Seftel et al. 2004. ^317^ Two distinct trials were reported in one publication (studies: a and b). ^145^ The summary of results for efficacy and harms of two trials ^5,^ ^77^ comparing combination of PDE-5 inhibitors versus PDE-5 inhibitors alone (and placebo) are presented also in the section for Question 1.

### Overview of Trials

Three trials used crossover, ^322,^ ^323,^ ^326^ and the remaining 17 used parallel design. Treatment duration in several trials was 6 months ^319,^ ^321,^ ^323,^ ^330^ and in one trial 12 months. ^316^ (Evidence Table F-9, Appendix 9)

### Populations

The mean age of the subjects in the trials was approximately 57 years. Racial characteristics were reported in only three trials with the majority of the subjects being Caucasians. ED etiology was physiologic in 89 percent of men, psychogenic in 4 percent, and mixed in 7 percent. Not all trials were comprised of exclusively patients with ED. ^5,^ ^77,^ ^145,^ ^231,^ ^322,^ ^326,^ ^329^ Several trials required a minimum duration of ED for study entry, of 3 months, ^5^ 5 months, ^329^ or 6 months. ^77,^ ^145,^ ^231,^ ^326^ Few trials were comprised of special populations: HIV positive men (n=74), ^325^ men with major depressive disorder (n=32), ^328^ obese men with type 2 diabetes (n=48), ^324^ and men with hypopituitarism (n=9). ^323^

While trials generally enrolled men with hypogonadism and/or andropause, the specific sexual dysfunction and testosterone entrance criteria across trials varied widely. With respect to testosterone, all but three trials ^145,^ ^323,^ ^326^ mandated that participants have levels below a specified threshold. Specific entrance criteria regarding total serum testosterone levels varied: 200–350 ng/dl, ^322^ ≤300 ng/dL, ^317,^ ^318,^ ^320,^ ^327,^ ^329^ ≤340–350 ng/dL, ^231,^ ^328^ <400 ng/dL, ^5^ <436 ng/dL, ^324^ and <500 ng/dL. ^325^ Additional trials required that participants have a low total testosterone (range of thresholds from 232 to 434 ng/dL) in combination with a low free testosterone, ^77^ low free androgen index, ^330^ a high SHBG, ^321^ or a free testosterone index between 0.3 and 0.5. ^316^ (Tables 23–26)

Table 23 Testosterone: Improvement in Sexual Intercourse Outcomes

Study/patient Characteristics | | Intervention Group 1 | Intervention Group 2 | Intervention Group 3 | Intervention Group 4
Cavallini 2004 Men >60 with symptoms of androgen decline and depressed mood | Treatment type | T 160 mg/d oral | Placebo | NA | NA
Cavallini 2004 Men >60 with symptoms of androgen decline and depressed mood | Number of patients at baseline | 40 | 45 | - | -
Cavallini 2004 Men >60 with symptoms of androgen decline and depressed mood | IIEF “Intercourse Satisfaction” (range 0–15): Median score at baseline (range) | 4 (3–6) | 4 (2–5) | - | -
IIEF “Intercourse Satisfaction”: Median score at end of therapy (6 months) | 5 (3–10) p <0.01 vs. baseline | 4 (3–5) | - | -
Seftel 2004 Hypogonadal men (secondary to aging and normo-gonadotrophic) | Treatment type | T gel 50 mg/d | T gel 100 mg/d | T patch ~25mg/d | Placebo
Seftel 2004 Hypogonadal men (secondary to aging and normo-gonadotrophic) | Number of patients at baseline | 99 | 106 | 102 | 99
Seftel 2004 Hypogonadal men (secondary to aging and normo-gonadotrophic) | Percentage of patients reporting no intercourse during baseline period | 45 | 47 | 49 | 43
% Improvement in frequency of intercourse from baseline at day 30 | +31 Extracted from graph p value vs. placebo <0.05 p value vs. T patch NS | +39 p value vs. placebo 0.0096 p value vs. T patch 0.0356 | +21 p value vs. placebo NS | +24 p value vs. T gel (50mg/d or 100mg/d) < 0.05 p value vs. T patch NS
Schiavi 1997 Men with ED and hypoactive sexual desire | Treatment type | T (IM) 200 mg | Placebo | NA | NA
Schiavi 1997 Men with ED and hypoactive sexual desire | Number of patients at baseline | 18 Crossover study (Washout period: 4 weeks) | 18 Crossover study (Washout period: 4 weeks) | - | -
Schiavi 1997 Men with ED and hypoactive sexual desire | Frequency of intercourse at baseline | NR | NR | - | -
Schiavi 1997 Men with ED and hypoactive sexual desire | Median frequency of “sex with partner” per week at week 6 | 1.25 (0–2) vs. Placebo: p value (NS) | 0.54 (0–2.7) vs. T (IM): p value (NS) | - | -
p value vs. placebo | NS | - | - | -
Gooma 2006 89 men with low testosterone levels and psychogenic and organic ED | Treatment type | T 0.8% + Isosorbide Dinitrate + Co-dergocrine Cream | Placebo | NA | NA
Gooma 2006 89 men with low testosterone levels and psychogenic and organic ED | Number of patients at baseline | 45 | 44 | - | -
Number of patients having full erections with successful intercourse at study end | 40% (18/45) | 0/44 | - | -
Gomaa 2001 Aged men with ED and hypoactive sexual desire | Treatment type | T 0.8% + Isosorbide Dinitrate + Co-Dergocrine Cream | T 0.8% cream | NA | NA
Gomaa 2001 Aged men with ED and hypoactive sexual desire | Number of patients at baseline | 42 Crossover study (washout period: 1 week) | 42 Crossover study (washout period: 1 week) | - | -
Gomaa 2001 Aged men with ED and hypoactive sexual desire | Frequency of intercourse at baseline | NR | NR | - | -
Gomaa 2001 Aged men with ED and hypoactive sexual desire | Mean number of full erections with satisfactory intercourse at 1 month (standard deviation) | 6.46 (2.7) | 4.05 (1.8) | - | -
Number of patients with full erections and satisfactory intercourse at 1 month | 66.7% (28/42) All patients 84.2% (16/19) Psychogenic 55.6% (10/18) Vascular 40% (2/5) Neurogenic | 31% (13/42) All patients 57.9% (11/19) Psychogenic 11.1% (2/18) Vascular 0% (0/5) Neurogenic | - | -
Cavallini 2004 Men >60 with symptoms of androgen decline | Treatment type | T (oral) 160 mg/d | Propionyl-L Carnitine + Acetyl-L Carnitine 2 g/d | NA | NA
Cavallini 2004 Men >60 with symptoms of androgen decline | Number of patients at baseline | 40 | 45 | - | -
Cavallini 2004 Men >60 with symptoms of androgen decline | IIEF Intercourse satisfaction): Median score at baseline | 4 (3–6) | 4 (3–7) | - | -
IIEF Intercourse satisfaction: Median score at end of therapy (6 months) | 5 (3–10) p <0.01 vs. baseline | 6 (3–10) p <0.01 vs. baseline | - | -

Table 24 Testosterone (T) Combined with PDE-5 inhibitors: Improvement in Sexual Intercourse Outcomes

Study/patient Characteristics | | Testosterone Group | Control Group | Relative risk (RR) or weighted mean difference (WMD) [95% CI]
Shabsigh 2004 Hypogonadal men, non-responders to sildenafil therapy | Treatment type | T 1% gel + Sildenafil 100mg | Placebo gel + Sildenafil 100mg
Shabsigh 2004 Hypogonadal men, non-responders to sildenafil therapy
Shabsigh 2004 Hypogonadal men, non-responders to sildenafil therapy | Number of patients at baseline | 39 | 36
Mean number of successful sexual attempts per week | 1.7–2.1 | 1.5–2.4 | -
Proportion (%) of successful sexual attempts per week | 49–59 | 43–50 | -
Aversa 2003 Men with arteriogenic ED | Treatment type | T 5 mg/d patch + Sildenafil 100mg | Placebo patch + Sildenafil 100mg
Aversa 2003 Men with arteriogenic ED
Aversa 2003 Men with arteriogenic ED | Number of patients at baseline | 10 | 10
Aversa 2003 Men with arteriogenic ED
Aversa 2003 Men with arteriogenic ED | Mean frequency of intercourse at baseline (SD) | 1.4 (0.6) | NR | NA
Mean frequency of intercourse at 1 month | 2.8 (0.9) | 1.5 (0.5) | WMD = 1.30 [0.66–1.94]
IIEF** Intercourse satisfaction (range 0–15): mean score at baseline | 7.1 (1.4) | 7.8 (1.8) | WMD = -0.70 [-2.11, 0.71]
IIEF Intercourse satisfaction: mean score at 1 month | 12.1 (1.6) | 7.7 (1.2) | WMD = 4.40 [3.16–5.64]
Yassin 2006 Hypogonadal men, non-responders to tadalafil therapy | Treatment type | T 50 mg/d gel + Tadalafil 20 mg | T 50 mg/d gel
Yassin 2006 Hypogonadal men, non-responders to tadalafil therapy | Number of patients at baseline | 34 | 35 | NA
Yassin 2006 Hypogonadal men, non-responders to tadalafil therapy
IIEF Intercourse satisfaction (range 0–15): mean score at baseline | 8.9 (2.8) | | NA
IIEF Intercourse satisfaction: mean score at 10 weeks | 13.1 (0.8) | 12.8 (0.9) | WMD = 0.30 [-0.10, 0.70]

* International Index of Erectile Dysfunction

Table 25 Testosterone Treatment: Improvement in Erections

Study/patient Characteristics | Outcome | Treatment Group | Control Group | Relative risk (RR) or weighted mean difference (WMD) [95% CI] or p value
Testosterone (IM) vs. Placebo
Seidman 2006 32 hyogonadal men with major depressive disorder | Full erection during phases of a normal sexual response cycle (foreplay through intercourse and orgasm) at baseline (standard deviation). Based on DSPS (range 0–8)* | 1.54 (1.94) | 1.18 (1.78) | NR
Seidman 2006 32 hyogonadal men with major depressive disorder
Seidman 2006 32 hyogonadal men with major depressive disorder | Full erection during phases of a normal sexual response cycle (foreplay through intercourse and orgasm) at study end. | 1.77 (2.17) Mean change = 0.23 | 1.53 (1.62) Mean change = 0.35 | p value (NS)
A satisfying orgasm at baseline. Based on DSPS (range 0–8)* | 1.92 (1.44) | 1.82 (1.81) | NR
A satisfying orgasm at end of study period | 2.31 (2.06) Mean change = 0.23 | 2.06 (1.44) Mean change = 0.35 | p value (NS)
Rabkin 2000 74 HIV positive men with hypogonadal symptoms | Completers who experienced ED rated as much to very much improved based on the Clinical Global Impression Scale | 62.5% (20/32) | 20.0% (4/20) | RR = 3.12 [1.25–7.82]
Clopper 1993 9 gonadotropin-deificent hypopituitary men | Self-reported weekly frequency of erection | 7.9 (6.1) | 4.9 (3.3) | p value (NS)
Testosterone (IM) vs. Human Chorionic Gonadotropin (IM)
Clopper 1993 9 gonadotropin-deificent hypopituitary men | Self-reported weekly frequency of erection | 7.9 (6.1) | 8.2 (7.1) | p value (NS)
Testosterone (oral) vs. Placebo
Haran 2005 | “Are your erections less strong?” % reporting yes after 12 months | 86% | 93% | p = 0.059
Cavallini 2004 95 men > 60 with symptoms of androgen decline | IIEF Erectile function (range 1–30): Median score at baseline (range) | 8 (5–19) | 8 (5–21) | NR
IIEF Erectile function: Median score at end of therapy (6 months) | 16 (6–29) | 8 (5–21) | Testosterone p <0.01 vs. baseline
Testosterone (oral) vs. No Treatment
Boyanov 2003 48 middle-aged men, with type 2 diabetes, obesity, and symptoms of androgen deficiency | IIEF-5 to assess erectile function, score at baseline (absent-1 to severe-5) | 2.25 (0.68) | 2.50 (0.75) | NR
IIEF-5 score after treatment (3 months) | 1.062 (0.90) | 2.25 (0.88) | p <0.05
Dihydrotestosterone Gel vs. Placebo Gel
Kunelius 2002 120 men with andropause symptoms | Based on difficulties in maintaining an erection during intercourse scale, scored from 1 (always) to 6 (never). A score of 3 indicates difficulties 50% of the time. | 3.24 (1.35) | 2.81 (1.56) | NA
Testosterone 50 mg Gel (T 50) vs. Testosterone 100 mg Gel (T 100) vs. Andropatch
McNicholas 2002 208 aging, hypogonadal men | Mean number of spontaneous erections/week at baseline | T 50: 0.8 T 100: 0.8 | Andropatch 0.9
Mean change in spontaneous erections/week after therapy (90 days) | T 50: +0.6 T 100: +0.5 | Andropatch +0.3 | T 50: p <0.05 vs. baseline T 100: p <0.05 vs. baseline
Wang 2000 227 hypogonadal men | % of full erections at baseline (estimated from graph) | T 50: 53 T 100: 60 | Andropatch 57% | NR
% of full erections at day 90 (estimated from graph) | T 50: 67 T 100: 68 | Andropatch 65% | p = 0.0001 for all groups vs. baseline
Testosterone 0.8% + Isosorbide Dinitrate + Co-Dergocrine Cream vs. Placebo
Gooma 2006 89 men with low testosterone levels | Full erection after treatment (2 months) | 40.0% (18/45) All patients 68.8% (11/16) Psychogenic 11.1% (1/9) Vascular 37.5% (3/8) Neurogenic 25% (3/12) Mixed | 0/44 | -
Testosterone 0.8% + Isosorbide Dinitrate + Co-Dergocrine Cream vs. Testosterone 0.8% cream
Gomaa 2001 42 aged men with ED and hypoactive sexual desire | Mean number of full erections with satisfactory intercourse at 1 month. | 6.46 (2.7) | 4.05 (1.8) | WMD = 2.41 [1.43–3.39]
Number of patients with full erections and satisfactory intercourse at 1 month | 66.7% (28/42) All patients 84.2% (16/19) Psychogenic 55.6% (10/18) Vascular 40.0% (2/5) Neurogenic | 31.0% (13/42) All patients 57.9% (11/19) Psychogenic 11.1% (2/18) Vascular 0% (0/5) Neurogenic | RR = 2.15 [1.31–3.55] RR = 1.45 [0.95–2.24] RR = 5.00 [1.27–19.68] -
Testosterone (oral) vs. Propionyl-L carnitine + Acetyl-L carnitine
Cavallini 2004 95 men > 60 with symptoms of androgen decline and depressed mood | IIEF Erectile function (range 1–30): Median score at baseline | 8 (5–19) | 8 (5–22) | NR
IIEF Intercourse satisfaction: Median score at end of therapy (6 months) | 16 (6–29) | 24 (8–29) | Testosterone p <0.01 vs. baseline Carnitines p <0.01 vs. baseline
Testosterone 5 mg/d Patch + Sildenafil 100mg vs. Placebo Patch + Sildenafil 100mg
Aversa 2003 20 men with arteriogenic ED | Global Assessment Questionnaire: “has treatment improved erections” | 80% (8/10) | 10% (1/10) | RR = 8.00 [1.21–52.69]
Aversa 2003 20 men with arteriogenic ED
IIEF** Intercourse satisfaction (range 1–30): mean score at baseline | 14.4 (1.4) | 13.2 (1.1) | WMD = 1.20 [0.10–2.30]
IIEF Intercourse satisfaction: mean score at 1 month | 21.8 (2.1) | 14.2 (0.7) | WMD = 7.60 [6.23–8.97]
Testosterone 1% Gel + Sildenafil 100mg vs. Placebo Gel + Sildenafil 100mg
Shabsigh 2004 75 hypogonadal men, non-responders to sildenafil therapy | Patients with IIEF-Q3/Q4: 4–5 ** at study end | 51.4% (19/37) | 39.4% (13/33) | RR = 1.30 [0.77–2.21]
Patients who increased functioning by at least 1 category over baseline for either IIEF Q3 or Q4 at week 12 | 78.8% (26/33) | 71.0% (13/31) | RR = 1.11 [0.83–1.48]
Testosterone (oral) + Sildenafil (50 or 100mg) vs. Testosterone (oral): sildenafil non-responder men
Shamloul 2005 Study a 20 men with ED associated with PADAM (partial androgen deficiency in aging men) | IIEF-5 to assess erectile function, score at baseline | 10.1 (1.3) Baseline | 9.9 (1.4) Baseline
IIEF-5 score after treatment | 15.0 (1.4) p <0.01 vs. baseline | 11.1 (1.5) p = 0.27 vs. baseline | WMD = 3.90 [2.63–5.17]
Testosterone (oral) + Sildenafil (50 or 100mg) vs. Sildenafil (50 or 100mg): men partially responding to sildenafil
Shamloul 2005 Study b 20 men with ED associated with PADAM (partial androgen deficiency in aging men) | IIEF-5 to assess erectile function, score at baseline | 15.3 (1.6) Baseline | 15.4 (1.2) Baseline | -
| IIEF-5 score after treatment | 17.5 (1.8) p <0.01 vs. baseline | 15.9 (1.3) p = 0.24 vs. baseline | WMD = 1.60 [0.22–2.98]

* Derogatis Sexual performance Scale. Range 0 (not at all) to 8 (4 or more times/day)

** Question 3: “Over the past 4 weeks, when you attempted sexual intercourse, how often were you able to penetrate your partner?” and Question 4: Over the past 4 weeks, during sexual intercourse, how often were you able to maintain your erection after you penetrated your partner?”

Table 26 Testosterone Treatment: Patients with Adverse Events

Study/patient Characteristics | Adverse Events | Treatment Group % (n/N) | Control Group % (n/N) | Absolute Risk Difference [95% CI]
Testosterone (IM) vs. Placebo
Seidman 2006 | No adverse events occurred except one placebo subject had a myocardial infarction.
Rabkin 2000 | Patients with ≥ 1 Irritability Acne Testicular atrophy Decreased ejaculate | 41 (16/39) 17.9 (7/39) 20.5 (8/39) 5.1 (2/39) 2.6 (1/39) Hair loss (n=1) Bossiness (n=1) | 20 (7/35) 17.1 (6/35) 0/35 0/35 2.9 (1/35) 0 0 | 21.0 [1.0–41.0] 1.0 [-17.0, 18.0] 21.0 [7.0–34.0] - -0.3 [-8.0, 7.0] -
Testosterone (oral) vs. Placebo
Cavallini 2004 | Mild epigastralgia | 2.5 (1/40) | 2.2 (1/45) | 0.3 [-6.0, 7.0]
Testosterone (oral) vs. No Treatment
Boyanov 2003 | No AE were reported during the study
Testosterone (Cream) vs. Placebo
Gooma 2006 | Headaches (transient) Skin irritation Prolonged erections/priarism | 11.1 (5/45) 2.2 (1/45) 0 | 0 (0/44) 0 (0/44) 0 | - - -
Testosterone (Gel) vs. Placebo
Seftel 2004 | Treatment-related (application site reactions, BPH, increases in blood pressure and hematocrit/hemoglobin, gyencomastia, headache, hot flashes, insomnia, mood swings, spontaneous erections) Skin reaction leading to study withdrawal | 29.3 (29/99) T 50 36.8 (39/106) T 100 0 | 40.4 (40/99) 0 | -11.0 [-24.0, 2.0] -4.0 [-17 to 10]
Dihydrotestosterone Gel vs. Placebo Gel
Kunelius 2002 | Mild headache Mild depression Hair growth | 5.0 (3/60) 3.3 (2/60) 1 patient | 3.3 (2/60) 3.3 (2/60) | 2.0 [-5.0, 9.0] -
Testosterone 0.8% + Isosorbide Dinitrate + Co-Dergocrine Cream vs. Testosterone 0.8% Cream
Gomaa 2001 | Mild transient headache PSA values: no significant increase of reported | N = 5 (phase 1 and 2) | 0 | -
Testosterone (patch) vs. Placebo
Merza 2005 | Increase in hematocrit Significant difference in the percentage change of hemoglobin between the two groups of 4% during phase 1 (p = 0.036). PSA: 25% increase testosterone vs. 6% for placebo (difference between the two means: NS) | 15 (3/20) n = 2 withdrawals in phase 2 | 5.3 (1/19) | 10 [-9 to 28]
| n =1 (angina)
Seftel 2004 | Treatment-related Skin reaction leading to study withdrawal | 62.7 (64/102) n = 15 | 40.4 (40/99) 0 | 22.0 [9.0–36.0] -
Testosterone 5 mg/d Patch + Sildenafil 100mg vs. Placebo Patch + Sildenafil 100mg
Aversa 2003 | No clinically significant adverse events were observed with both treatments
Testosterone 50 mg Gel (T 50) vs. Testosterone 100 mg Gel (T 100) vs. Andropatch
McNicholas 2002 | Patients reporting ≥ 1 treatment-emergent (erythema, irritation and reactions at application site) | 35.3 (24/68) T 50 29.2 (21/72) T 100 | 63.2 (43/68) Patch | -28.0 [-44.0, -12.0] -34.0 [-50.0, -19.0]
Skin irritation | “Very low Incidence” - both groups | 47% at day 30 and 53% after 90 days | -
Wang 2000 | Skin irritation Urogential events Serum PSA levels elevated to above the normal range Gynecomastia (2 of the patients had preexisting gynecomastia) One patient in T 50 group had depression (discontinued); one patient in T 100 group had high blood pressure (discontinued), and one patient had memory loss/sadness (discontinued); One patient in Patch group discontinued due to elevated hematocrit and hemoglobin | 5.7 (3/53) T 50 5.3 (3/57) T 100 9.6 (7/73) T 50 5.1 (4/78) T 100 1.4 (1/73) T 50 5.1 (4/78) T 100 1.4 (1/73) T 50 3.8 (3/78) T 100 | 65.8 (50/76) Patch 0 (0/76) Patch 0 (0/76) Patch 0 (0/76) Patch | -60.0 [-72.0, -48.0] -61.0 [-73.0, -48.0] - - - - - -
Testosterone (oral) vs. Propionyl-L Carnitine + Acetyl-L Carnitine
Cavallini 2004 | Mild headache | 0 (0/40) | 2.2 (1/45) | -
Testosterone 1% Gel + Sildenafil 100mg vs. Placebo Gel + Sildenafil 100mg
Shabsigh 2004 | One patient on testosterone withdrew from the study because of an AE. No further details were provided.
Testosterone (oral) + Sildenafil (50 or 100mg) vs. Testosterone alone or Sildenafil (50 or 100mg) alone
Shamloul 2005 | No significant adverse events observed (mild headache in three patients on sildenafil 100mg) Slight increase in serum PSA (NS)
Testosterone 50 mg/d Gel + Tadalafil 20 mg vs. Testosterone 50 mg Gel
Yassin 2006 | No adverse events observed

* Derogatis Sexual Performance Scale. Range 0 (not at all) to 8 (4 or more times/day)

### Interventions

Of the 21 trials involving testosterone therapy for treatment of male ED, most assessed testosterone monotherapy including oral, ^145,^ ^316,^ ^319,^ ^324^ intramuscular (IM), ^325,^ ^326,^ ^328^ gel, ^231,^ ^317,^ ^320,^ ^327^ patch, ^317,^ ^320,^ ^327,^ ^330^ and cream forms. ^322,^ ^329^ Five trials studied testosterone in combination with a phosphodiesterase inhibitor. ^5,^ ^77,^ ^145,^ ^231^ Two other trials studied a cream combining testosterone, isosorbide dinitrate and co-dergocrine. ^322,^ ^329^ Finally, one trial compared dihydrotestosterone gel versus placebo. ^321^

### Study Quality and Reporting

Information on pharmaceutical funding was provided for seven trials. ^5,^ ^316,^ ^317,^ ^320,^ ^321,^ ^327,^ ^330^ Only three studies reported using an intention to treat analysis. ^5,^ ^316,^ ^317^ Three of the trials reported adequate allocation concealment ^319,^ ^322,^ ^325^ and six trials an appropriate double-blinding method. ^5,^ ^316,^ ^321,^ ^322,^ ^325,^ ^329^ There was adequate description of study withdrawals, drop-outs by treatment group in eight trials. ^5,^ ^231,^ ^321,^ ^324,^ ^325,^ ^327,^ ^328,^ ^330^ Three trials received a total Jadad score of 5, ^5,^ ^321,^ ^325^ two trials received a score of 2, ^316,^ ^330^ and four received a score of 3. ^322,^ ^327,^ ^329,^ ^331^ The remainder received a score of 2 or less.

### Outcomes

The eighteen eligible trials utilized diverse efficacy outcome measures. Seven trials reported data on frequency of successful sexual intercourse attempts. ^5,^ ^77,^ ^231,^ ^317,^ ^322,^ ^326,^ ^329^ Three other trials reported data on the frequency of full erection during intercourse or the ability to maintain erection during sexual intercourse, ^321,^ ^326,^ ^328^ and three trials reported intercourse satisfaction. ^77,^ ^231,^ ^319^ Other reported outcomes were IIEF-EF ^5,^ ^77,^ ^145,^ ^319,^ ^324^ and the Male Erectile Dysfunction Quality of Life questionnaire. ^330^ Two trials reported data for sexual performance defined as the frequency of days with either orgasm, erection, masturbation, ejaculation and/or intercourse in the past week. ^320,^ ^327^

Finally, several trials reported data on erections (e.g. frequency of erections, ^323^ improvement in erections, ^77,^ ^316,^ ^325^ satisfaction with erections, ^327^ and full erections with sexual interest). ^322^ With respect to harms outcomes, five trials reported no adverse effects data. ^5,^ ^316,^ ^323,^ ^324,^ ^326^ Several trials reported that adverse effects were absent ^231^ or were negligible and without a difference in frequency between treatment groups. ^77,^ ^145,^ ^319^ Data on specific adverse events were reported in only a minority of trials, including skin irritation, ^329,^ ^332^ increased PSA, ^77,^ ^317,^ ^322,^ ^329,^ ^330^ headache, ^145,^ ^319,^ ^321,^ ^322,^ ^329^ and worsening of lower urinary tract symptoms. ^317^

### Qualitative Synthesis

Oral testosterone versus no treatment. In one open label trial outcomes for efficacy and harms were compared between oral testosterone and no treatment. ^324^ In this study, 48 diabetic men aged 45–65 years, with ED, increased abdominal girth, and symptoms of mild androgen deficiency, (total testosterone <15.1 nmol/L) were randomized to either 120 mg oral testosterone undecanoate taken daily for 3 months or no treatment. Subjects were excluded from the trial if they had prostate abnormality or any illness considered likely to impair sexual function.

Harms. No adverse events were reported for this trial.

Efficacy. There was a statistically significant improvement in mean IIEF-5 scores (1=absent, 2=mild, 3 = mild to moderate, 4 = moderate, and 5 = severe) at 3 months in testosterone-treated patients compared with those with no treatment assigned (1.06 versus 2.25, p < 0.05).

Oral testosterone versus placebo. The outcomes for efficacy and harms associated with the use of oral testosterone versus placebo were compared in two trials. ^316,^ ^319^ In the first trial, 150 men aged 60–74 years, with symptoms attributed to androgen decline, including decreased libido and erectile quality, and free testosterone <6 pg/ml, were randomized to either 160 mg oral testosterone undecanoate taken daily for 6 months, or 2 gm propionyl-L-carnitine plus 2 gm acetyl-L-carnitine daily or placebo. ^319^ Exclusion criteria were prostate enlargement, elevated PSA, and significant LUTS. In the second trial, 76 men aged 60–86 years, with at least two symptoms on the ADAM questionnaire, total testosterone <8 nmol/L, and a free testosterone index (FTI) between 0.3 and 0.5, were randomized either to 80 mg oral testosterone undecanoate taken twice daily for 12 months or placebo. ^316^ Patients with a history of prostate cancer, elevated PSA, and significant LUTS were excluded.

Harms. In the first trial, the difference in the occurrence of adverse events between the two treatment groups was not statistically significant. Epigastralgia was reported in 2.5 percent of testosterone-treated versus 2.2 percent of placebo-treated subjects. In the second trial, the occurrence of adverse events was not reported.

Efficacy. In the first trial ^319^ , men assigned to receive testosterone had median IIEF sexual intercourse satisfaction scores (range 0–15) of 5 (range 3–10) at 6 months (p <0.01). The corresponding median score for patients receiving placebo was 4 (range 3–5). The median IIEF-“EF domain” scores at 6 months of followup for men assigned to receive testosterone and placebo were 16 (range 6–29) and 8 (range 5–21), respectively. ^319^ In the second trial, 86 percent and 93 percent of men in the testosterone and placebo group, respectively, reported that their erections were “less strong” at 12 weeks of the followup. ^316^

Oral testosterone versus oral testosterone plus sildenafil. One trial evaluated and compared the efficacy and harms between oral testosterone alone and oral testosterone combined with sildenafil. ^145^ This study enrolled 20 men (mean age: 56 years) with ED of >6 months duration and symptoms of partial androgen deficiency (mean baseline total testosterone 7.3 nmol/L) who failed to respond to 50–100 mg sildenafil given twice weekly for 2 weeks. These men were randomized to 2 months of treatment with either oral testosterone undecanoate alone (120 mg/d) or oral testosterone undecanoate (120 mg/d) plus sildenafil (50–100 mg). Patients with prostate hypertrophy, prostate cancer, and mammary carcinoma were excluded.

Harms. The study reported that apart from mild headache occurring in three patients taking sildenafil 100 mg, no serious adverse events were observed. ^145^

Efficacy. Men in the oral testosterone group reported no significant change in their IIEF-5 scores from 9.9 (SD 1.4) at baseline to 11.1 (1.5) at 2 months (p = 0.27), whereas men in the oral testosterone plus sildenafil group scored 10.1 (1.3) at baseline and 15.0 (1.4) at 2 month followup (p < 0.01).

Oral testosterone versus propionyl-L-carnitine plus acetyl-L-carnitine. One trial evaluated and compared the efficacy and harms for oral testosterone versus propionyl-L-carnitine plus acetyl-L-carnitine. ^319^ In this study, 150 men aged 60–74 years, with symptoms of androgen decline, and free testosterone below 6 pg/mL, were randomized to receive either 160 mg oral testosterone undecanoate daily for 6 months or 2 gm propionyl-L-carnitine plus 2 gm acetyl-L-carnitine daily or placebo. ^319^ Exclusion criteria were prostate enlargement, elevated PSA, and significant LUTS. Results comparing testosterone and propionyl-L-carnitine plus acetyl-L-carnitine are reported here.

Harms. The occurrence of adverse events was not statistically significantly different between the two treatment groups. Epigastralgia was reported in 2.5 percent of the testosterone-treated versus 0 percent of propionyl-L-carnitine plus acetyl-L-carnitine-treated subjects. Mild headache was reported for 2.2 percent of the propionyl-L-carnitine plus acetyl-L-carnitine-treated subjects versus 0 percent for testosterone-treated subjects.

Efficacy. At 6 months, in men assigned to receive testosterone, the median IIEF-“EF domain” score changed from 8 (range 5–19) at baseline to 16 (range 6–29) (within-group difference: p <0.01). The corresponding median score in those assigned to the propionyl-L-carnitine plus acetyl-L-carnitine group changed from 8 (range 5–22) to 24 (range 8–29) (within-group difference: p <0.01).

Oral testosterone plus sildenafil versus sildenafil. One trial evaluated and compared the efficacy and harms outcomes of oral testosterone plus sildenafil compared with sildenafil alone. ^145^ This study enrolled 20 men (mean age: 56 years) with ED of > 6 months and symptoms of partial androgen deficiency (mean baseline total testosterone 7.3 nmol/L) who partially responded to previous sildenafil therapy (50–100 mg twice weekly for 2 weeks). The men were randomized to receive a 2-month treatment with either oral testosterone undecanoate (120 mg daily) plus sildenafil (50–100 mg) or sildenafil alone. Patients with prostate hypertrophy, prostate cancer, and mammary carcinoma were excluded.

Harms. Apart from mild headaches occurring in three patients taking sildenafil 100 mg, no serious adverse events were observed.

Efficacy. At 2 months of followup, the difference in mean IIEF-5 scores between patients who received the oral testosterone plus sildenafil versus the sildenafil monotherapy groups was not statistically significant (17.5 versus 15.9, p ≥ 0.05).

Intramuscular Testosterone (IM) versus placebo. Four trials compared the efficacy and harms of IM testosterone and placebo. ^323,^ ^325,^ ^326,^ ^328^

In the first trial, ^323^ nine gonadotropin-deficient males aged 15 years or older (range 16–20) and currently being treated for hypopituitarism, only 3 of whom had partners, were randomized to 1 cc IM testosterone enanthate every 2 weeks versus 2000 units human chorionic gonadotropin three times weekly versus placebo. The active treatment arms each lasted for at least 6 months, while the placebo treatment lasted for 2 months.

In the second trial, ^326^ 18 men, aged 45–74 years, with ED) were randomized either to IM testosterone enanthate 200 mg given twice weekly for 6 weeks or IM placebo. Patients with major disorders, a history of substance abuse, obesity, or major psychopathology were excluded from the trial.

In the third trial, ^325^ 74 HIV-positive men (CD4 <400), with ED or substantial loss of sexual desire, with low-to-normal levels of total testosterone (<22.6 nmol/L if the patient had AIDS plus wasting or fatigue, or otherwise <17.4 nmol/L) and at least one mood symptom of hypogonadism, were randomized either to IM testosterone cypionate 400 mg given twice daily for 6 weeks or placebo.

In the fourth trial, ^328^ 32 men ≥ 35 years (mean age: 52 years) with depression and total testosterone 350 ng/dL were randomized either to IM testosterone enanthate 200 mg given once weekly for 6 weeks or IM placebo. Patients with psychiatric disorders or abnormal prostate exam result (men aged > 50 years) were excluded.

Harms. In two trials, ^323,^ ^326^ no adverse events were reported. In the third trial, ^325^ men who received testosterone were more likely to report acne (testosterone: 20.5 percent versus placebo: 0 percent). Differences between men in the testosterone and placebo groups with respect to the occurrence of irritability (17.9 versus 17.1 percent) and testicular atrophy (5.1 versus 0 percent), were not statistically significant. In the fourth trial, ^328^ it was reported that no adverse events occurred except that one placebo-treated subject had a MI.

Efficacy. In the first trial, ^323^ weekly frequency of erections in the testosterone and placebo treatment groups were 7.9 (SD 6.1) and 4.9 (SD 3.3), respectively. The between-group difference was not statistically significant.

In the second trial, ^326^ results were based on 12 (67 percent) men who completed all assessments. At week 6, men in the IM testosterone group reported a median number of “sex with partner” of 1.25 times per week versus 0.54 times per week for men in the placebo group (between-group difference: p ≥ 0.05). There was no difference in the degree of erection during sex with partner (scale 1–6, with = “none” and 6 = “full”), with a mean score of 5.5 for each group, or in the degree of erection during masturbation.

In the third trial, ^325^ results were reported for the 52 men (70 percent) who completed the treatment schedule. Within this group, 62.5 percent of men who received testosterone versus 20 percent of those who received placebo reported that their erectile function was much or very much improved (RR = 3.12, 95 percent CI: 1.25–7.82).

In the fourth trial, ^328^ the difference in frequency (1 = less than 1 per month” and 2 = 1–2 per month”) of full erections during one month between men in the IM testosterone and IM placebo groups was not statistically significant (1.77 versus 1.53)

Testosterone (IM) versus human chorionic gonadotropin (IM). One trial compared the efficacy and harms of IM testosterone versus IM human chorionic gonadotropin. ^323^ In this trial, 9 gonadotropin-deficient men aged 15 years or older (range 16–20) being treated for hypopituitarism, were randomized to 1 cc IM testosterone enanthate given every 2 weeks versus 2000 units of human chorionic gonadotropin 3 times weekly versus placebo. The active treatment arms each lasted for at least 6 months, while the placebo treatment lasted for 2 months.

Harms. No adverse event data were reported.

Efficacy. The weekly frequency of erection was not different between the two groups of testosterone and human chorionic gonadotropin treatment (7.9 versus 8.2).

Gel testosterone versus placebo. The efficacy and harms of gel testosterone versus placebo were compared in one trial ^317^ In this trial, 406 hypogonadal men (total T <300 ng/dL) aged 20–80 years (mean age: 58 years) reporting one or more symptoms of low testosterone deficiency (i.e. fatigue, decreased muscle mass, reduced libido), were randomized to 50 mg gel testosterone (Testim) daily versus 100 mg gel testosterone (Testim) daily versus 24.4 mg patch testosterone (Androderm) versus placebo.

Harms. In total, 29.3 percent of men receiving 50 mg gel testosterone; 36.8 percent receiving 100 mg gel testosterone and 40.4 percent receiving placebo reported at least one treatment-related adverse event (including application site reactions, BPH, increase in blood pressure, increase in hematocrit, gynecomastia, headache, hot flashes, insomnia, mood swings, or spontaneous erections). These differences were not statistically significant. One participant from the group treated with 50 mg gel testosterone, five in the group treated with 100 mg gel testosterone, and none treated with placebo withdrew due to an adverse event.

Efficacy. At day 30, among men with sexual partners (63 percent of randomized men), 24 percent of placebo-treated men reported an increase from baseline in the number of days in the past week with sexual intercourse, compared with 31 percent of 50 mg gel testosterone-treated men (p <0.05 versus placebo) and 39 percent of 100 mg gel testosterone men (p = 0.0096 versus placebo).

Gel testosterone versus patch testosterone. The efficacy and harms of gel testosterone versus patch testosterone was compared in three trials. ^317,^ ^320,^ ^327^ In the first trial, ^327^ 227 men aged 19–68 years (mean age: 58 years) with total testosterone levels <10.4 nmol/L (300 ng/dL) were randomized to 50 mg gel testosterone (Androgel) given daily versus 100 mg gel testosterone (Androgel) given daily versus 5 mg patch testosterone (Androderm) given daily. Patients with increased PSA, significant skin disease, and substantial under- or overweight were excluded.

The other two trials ^317,^ ^320^ had similar protocols. The inclusion criteria were low total testosterone (≤10.4 nmol/l ^320^ and ≤300 ng/dL ^317^ ) and/or symptoms of hypogonadism (i.e. fatigue, decreased muscle mass, reduced libido, or “reduced sexual functioning” of nonmechanical origin). Both trials randomized men to 50 mg gel testosterone (Testim) daily versus 100 mg gel testosterone (Testim) daily (deliver a daily dose of 5 and 10 mg testosterone, respectively). The first of these trials included an additional group randomized to 5 mg patch testosterone (Andropatch), ^320^ and the second trial randomized two additional groups to 24.4 mg patch testosterone and placebo. ^317^

In the first of these trials, ^320^ men were to remain on their initially assigned treatment dose throughout the 90 day study, but in the second trial, ^317^ titration from the initial gel testosterone dose was possible at 60 days.

Harms. In the first trial, ^327^ skin irritation was reported by 5.7 percent of men who received 50 mg gel testosterone, 5.3 percent of those who received 100 mg gel testosterone, and 65.8 percent of those who received patch testosterone. Urogenital adverse events (e.g. prostate enlargement, increased PSA) were reported by 9.6 percent of men who received 50 mg gel testosterone, 5.1 percent of those who received 100 mg gel testosterone, and 0 percent of those who received patch testosterone.

In the other two trials, ^317,^ ^320^ approximately 30–35 percent of men who received either of the gel testosterone groups versus 60 percent of those who received patch testosterone reported at least one treatment-related adverse event. Most common adverse events were skin application site reactions and less frequent events were BPH, increase in blood pressure, increase in hematocrit, gynecomastia, headache, hot flashes, insomnia, mood swings, or spontaneous erections. The second of these trials ^317^ reported that withdrawals due to adverse events occurred in one 50 mg gel testosterone subject, five 100 mg gel testosterone subjects, and 15 patch testosterone subjects. In the same trial, two patients in the patch testosterone arm were diagnosed with prostate cancer. ^317^

Efficacy. In the first trial, ^327^ patients in the gel testosterone group experienced slightly greater sexual enjoyment compared with those receiving the testosterone patch (p = 0.0113).

In the second trial, ^320^ compared with baseline, men in the 50 mg gel testosterone, 100 mg gel testosterone, and patch testosterone groups experienced 38, 50 and 33 percent improvement in “sexual performance” (within-group comparison: p <0.05; between-group comparisons: p ≥ 0.05). Similarly, all three groups significantly improved from baseline, but without between-group differences for the domains of sexual motivation and sexual desire. Although spontaneous erections were significantly increased in frequency compared with baseline in both gel testosterone groups, and not in the patch testosterone group, there were no significant between-treatment group differences.

In the third trial, ^317^ at baseline approximately 20 percent of men reported having no sexual partner available, and approximately 45 percent reported no sexual intercourse during the past week. At day 30, among men with sexual partners for whom these data were reported (61 percent of randomized men), 31 percent of 50 mg gel testosterone men reported an increase from baseline in the number of days in the past week with sexual intercourse versus 39 percent of 100 mg gel testosterone men (versus 50 mg, p ≥ 0.05, and versus patch, p = 0.03) and 21 percent of patch testosterone men (versus 50 mg group, p ≥ 0.05).

Gel testosterone versus gel testosterone plus tadalafil. One trial compared the efficacy and harms of gel testosterone versus gel testosterone plus tadalafil. ^231^ This trial enrolled 69 hypogonadal men (total testosterone <3.4 ng/ml) aged 34–78 years (mean: 59 years), who had >6 months of ED and a history of nonresponse (i.e. poor IIEF score or persistent patient/partner dissatisfaction) to 20 mg tadalafil. Men were randomized to 50 mg gel testosterone (Testogel) daily for 4 weeks followed by concurrent treatment with tadalafil 20 mg twice weekly for 9 weeks versus 50 mg gel testosterone (Testogel) daily for 10 weeks followed by concurrent treatment with tadalafil 20 mg twice weekly for 3 weeks. All treatments were open label.

Harms. No adverse events were observed.

Efficacy. At 10 weeks, there was no difference between treatment groups in mean IIEF intercourse satisfaction score (13.1 +/- 0.8 versus 12.8 +/- 0.9, WMD = 0.30, 95 percent CI: -0.10 to 0.70). After 13 weeks, 66.7 percent of patients were rated sufficient to good for successful intercourse completion in group one versus 63.6 percent in group two (RR = 1.05, 95 percent CI: 0.68– 1.62), and 47.6 percent of patients were rated sufficient to good for intercourse frequency in group one versus 59.1 percent in group two (RR = 0.81, 95 percent CI: 0.46–1.42).

Gel testosterone plus sildenafil versus sildenafil. This double-blind trial ^5^ studied 75 men aged 26–79 years (mean age: 58 years) with ED of >3 months, and total testosterone <400 ng/dL. The men, refractory to prior sildenafil therapy were randomized to 1 percent gel testosterone daily plus 100 mg sildenafil once daily for each day with sexual activity as needed for 12 weeks versus 100 mg sildenafil as needed. Exclusion criteria were: history of prostate cancer, prostate disease with diminished urine flow rate, neurologic ED, substance abuse, or significant or uncontrolled medical or psychiatric conditions.

Harms. One subject in gel testosterone plus sildenafil arm withdrew due to adverse events. There were no withdrawals due to adverse events among patients receiving sildenafil alone.

Efficacy. In men receiving gel testosterone plus sildenafil, the mean number of successful sexual attempts (per week) ranged from 1.7 to 2.1. The corresponding range for those receiving sildenafil was 1.5–2.4 per week. At the end of the study, the proportions of men with scores of 4–5 on IIEF-Q3/Q4 was statistically nonsignificantly greater in the combination therapy group than in the sildenafil only group (51.4 versus 39.4 percent; RR = 1.30, 95 percent CI: 0.77–2.21). Men who received gel testosterone plus sildenafil had greater mean change from baseline in the IIEF “EF” domain score compared with those receiving sildenafil and placebo. The between-group differences were statistically significant at week 4 (4.4 versus 2.1, 95 percent CI: 0.3–4.7).

Cream testosterone versus cream testosterone plus isosorbide dinitrate plus co-dergocrine. One trial compared the efficacy and harms of cream testosterone versus cream testosterone plus isosorbide dinitrate plus co-dergocrine. ^322^ In this two phase crossover trial, 42 men aged 41–67 years (mean: 54 years) with ED, decreased libido and total testosterone 200–350 ng/dl were randomized to 0.8 percent cream testosterone versus 0.8 percent cream testosterone plus 0.5 percent isosorbide dinitrate plus 0.06 percent co-dergocrine. Each treatment was to be applied daily at bedtime to the penile shaft and glans; if intercourse was going to occur then the cream was applied 15 minutes before intercourse. Each arm of the crossover lasted 30 days.

Harms. Five men who received combination therapy reported a mild transient headache versus none who received cream testosterone alone. No significant increase in PSA occurred.

Efficacy. In total 67 percent of men who received cream testosterone plus isosorbide dinitrate plus co-dergocrine reported a complete response to treatment (full erection and sexual interest compared with 31 percent of men who received cream testosterone alone (RR = 2.15, 95 percent CI: 1.31–3.55). Among men with psychogenic ED (n = 19), 84.2 percent of those who received combination therapy reported a complete response versus 57.9 percent of those who received cream testosterone alone (RR =1.45, 95 percent CI: 0.95–2.24). Among men with vascular ED (n=18), 55.6 percent of those who received combination therapy reported a complete response versus 11.1 percent of those who received cream testosterone alone (RR = 5.00, 95 percent CI: 1.27–19.68). Among men with neurogenic ED (n = 5), two who received combination therapy reported a complete response versus none who received cream testosterone alone. Among all men with complete responses, those who received cream testosterone plus isosorbide dinitrate plus co-dergocrine reported a mean of 6.46 (SD 2.7) full erections with satisfactory intercourse per month versus 4.05 (SD 1.8) for men who received cream testosterone only (WMD = 2.41, 95 percent CI: 1.43 to -3.39).

Cream testosterone plus isosorbide dinitrate plus co-dergocrine versus placebo. One trial compared the efficacy and harms of cream testosterone plus isosorbide dinitrate plus co-dergocrine versus placebo. ^329^ ) In this trial, 89 men aged 35–65 years (mean: 54 years) with more than 5 months of decreased libido and of decreased frequency and quality of sexual erections, and total testosterone <300 ng/dL, were randomized to 0.8 percent cream testosterone plus 0.5 percent isosorbide dinitrate plus 0.06 percent co-dergocrine versus placebo. Each treatment was applied twice daily to the shoulder for two months. Patients with abnormal rectal exam results, PSA >4 ng/ml, and urine flow rate <12 ml/second were excluded.

Harms. Among men who received combination treatment, 11.1 percent reported headaches, 2.2 percent reported skin irritation (versus 0 percent for placebo subjects). Neither treatment group reported priapism.

Efficacy. Of men who received combination therapy, 40 percent reported at least one full erection with successful intercourse during followup versus 0 percent of those who received placebo. No men who received placebo reported full erections after two months of treatment in any ED etiology subgroup, whereas among men who received combination treatment, full erections were reported by 68.8 percent of men with psychogenic ED (n = 11/16), 11.1 percent of men with vascular ED (n = 1/9), 37.5 percent of men with neurogenic ED (n = 3/8), and 25 percent of men with mixed ED (n = 3/12). Men who received combination therapy also reported improved enjoyment with partner and satisfaction with intercourse.

Patch testosterone versus placebo. The efficacy and harms of patch testosterone versus placebo were evaluated and reported in two trials. ^317,^ ^330^ The design and study population of the first trial ^317^ are described elsewhere in two other sections: Gel Testosterone versus Placebo and Gel Testosterone versus Patch Testosterone. In the second trial, ^330^ 39 “borderline” hypogonadal men (total testosterone <10 nmol/l or a free androgen index <30 percent) aged 40–77 years (mean: 62 years) were randomized to 6 months of treatment either with 5 mg patch testosterone (Testoderm) once daily or placebo.

Harms. In the first trial, ^317^ 62.7 percent of men assigned to the patch testosterone group versus 40.4 percent of those in the placebo group had at least one treatment-related adverse event. Withdrawals due to a skin reaction occurred in 15 percent of patch testosterone subjects, but not in placebo subjects.

In the second trial, ^330^ 15 percent of patch testosterone subjects and 5.3 percent of placebo subjects had an increased hematocrit. One subject assigned to the placebo group developed angina.

Efficacy. In the first trial, ^317^ , among men with sexual partners (62 percent of randomized men), 24 percent of men receiving placebo reported an increase from baseline in the number of days in the past week with sexual intercourse, compared with 21 percent of men receiving patch testosterone (p ≥ 0.05, versus placebo).

In the second trial, ^330^ men who received placebo had a statistically significantly greater decline from baseline in their Male Erectile Dysfunction Quality of Life questionnaire (MEDQoL) score (range 0–100) compared with men who received patch testosterone (from 61.4 at baseline to 61.8 at followup for patch testosterone versus from 54.2 at baseline to 43.6 at followup for placebo) (p = 0.017).

Patch testosterone plus sildenafil versus sildenafil. One open label trial compared the efficacy and harms of patch testosterone plus sildenafil versus sildenafil. ^77^ This trial enrolled 20 men aged 48–66 years (mean age: 56 years), with arteriogenic ED of ≥6 months duration, and refractory to prior sildenafil therapy, The inclusion criteria were: total testosterone 10–13 nmol/L and free testosterone 200–300 pmol/lL, no response to previous treatment with 100 mg patch testosterone, and an IIEF erectile function score of less than 24 in response to 100 mg sildenafil. Men with a history of hematological disorders or prostate disease were excluded. Men were randomized to 5 mg patch testosterone daily plus 100 mg sildenafil, as needed for one month versus placebo patch daily plus 100 mg sildenafil, as needed.

Harms. Data on adverse events was not reported.

Efficacy. Men who received placebo patch plus sildenafil did not improve in erectile function compared with baseline on any IIEF question or domain reported. Those in the combination group (patch testosterone plus sildenafil) had a greater endpoint percentage of successful intercourse attempts (data not provided), higher “EF domain” scores (21.8 +/- 2.1 versus 14.2 +/- 0.7, WMD = 7.60, 95 percent CI 6.23–8.97), an increased number of sexual intercourses (2.8 +/- 0.9 versus 1.5 +/- 0.5, WMD = 1.30, 95 percent CI 0.66–1.94), greater intercourse satisfaction (12.1 +/- 1.6 versus 7.7 +/- 1.2, WMD = 4.40, 95 percent CI 3.16–5.64), and more frequently reported that treatment had improved their erections (80 versus 10 percent, RR = 8.00, 95 percent CI: 1.21–52.69).

Dihydrotestosterone gel versus placebo. One trial compared the efficacy and harms of dihydrotestosterone gel versus placebo. ^321^ This trial enrolled 120 men with nocturnal penile tumescence no more than once weekly, at least one symptom of andropause (decreased libido, ED, “urinary disorder,” asthenia, or depressed mood), and total serum testosterone <15 nmol/L and/or SHBG >30 nmol/L. Men were randomized to daily dihydrotestosterone gel versus placebo for 6 months. Dihydrotestosterone gel was initiated at 125 mg daily and could be titrated to 250 mg daily after 30 days according to DHT levels.

Harms. Of men who received dihydrotestosterone gel, 5 percent reported mild headache (versus 3.3 percent for placebo) and 3.3 percent reported mild depression (versus 3.3 percent for placebo).

Efficacy. At baseline and 6-month followup, participants rated their ability to maintain erection during intercourse on a scale of 1–6, in which 2 = “75 percent of intercourses” and 3 = “50 percent of intercourses. Mean scores reported for participants who received dihydrotestosterone were 2.26 at baseline and 3.24 at 6 months, whereas those for the participants in the placebo group were 2.53 at baseline and 2.81 at followup (p = 0.04 for mean change from baseline between treatment groups).

### Quantitative Synthesis

There was a large degree of clinical heterogeneity in the eligible testosterone trials with regard to patient characteristics (e.g. characterization of sexual dysfunction, testosterone level), interventions (e.g. specific testosterone formulation, dose and duration of treatment, use of testosterone monotherapy or combination), and outcomes assessed (e.g. various definitions of sexual intercourse success, and of erection improvement). Therefore, no MA was performed.

## Other Treatments (Off Label)

### Literature Search

There were 21 (in 22 publications) unique studies reporting on different off label oral treatments that met the eligibility criteria of this review. ^265,^ ^333^ – ^353^

Note: Korenman et al. (1994) ^349^ is a reprint of Korenman et al. (1993). ^345^

### Overview of Trials

The trials evaluated the following treatments: phentolamine (one additional trial of phentolamine is described in the Sildenafil section ^124^ ), ^333,^ ^338^ trazodone, ^336,^ ^337,^ ^339,^ ^341,^ ^344^ cabergoline, ^162,^ ^350^ pentoxifyling (in 4 reports), ^340,^ ^343,^ ^345,^ ^349^ and miscellaneous medications. The latter consisted of treatments with moclobemide, ^334^ isoxsuprine, ^335^ opiate antag, ^342^ ACE, ^346^ moxonidine, ^347^ dehydropiand, ^348^ tetrahydrobiopterin (BH4), ^353^ Myoinositol, ^351^ and Tianeptine. ^352^ (Table F-10, Appendix F)

Phentolamine. Two trials investigated the effect of phentolamine in comparison to placebo. ^333,^ ^338^ One of the trials was used a crossover design (n = 5) ^333^ and the other a parallel design (n = 44). ^338^ Subjects in these trials were generally older than 18 years, with ED of at least 3 months of duration and various etiologies (the majority with organic causes). Total Jadad score was 3 for both trials. ^333,^ ^338^ The allocation concealment was unclear for both trials. The trial outcomes were patient diary ^338^ and RigiScan measures on nocturnal erectile activity. ^333^

Harms. One trial reported one adverse event occurring in a patient taking 60 mg dose. ^338^ In another trial, no adverse events occurred. ^333^ No serious adverse events were reported in any of these trials.

Efficacy. Forty to 50 percent of patients improved their erections with higher doses of phentolamine (40 and 60 mg) compared with 30 and 20 percent with lower dose (20 mg) or placebo respectively. ^338^

Oral phentolamine (40 mg, 3 consecutive nights) administered before sleep increased the number of erectile events with rigidity of at least 60 percent lasting at least 10 minutes (p = 0.02), and the rigidity activity unit (RAU) per hour of sleep both at the base (p = 0.023) and the tip of the penis (p = 0.019), which were not different from changes after administration of placebo. ^333^

Trazodone versus other active treatment versus placebo. Five trials reported on the effect of treatment with trazodone (n = 333, range: 34–100 participants). ^336,^ ^337,^ ^339,^ ^341,^ ^344^ The trials were conducted in Belgium, ^336^ Turkey, ^341,^ ^344^ the Netherlands, ^339^ and US. ^337^ Total Jadad score ranged from 1 ^341^ to 4 ^339^ with a mean of 2.8.

Four studies used a parallel ^336,^ ^339,^ ^341,^ ^344^ , and one crossover design. ^337^ Trazodone was administered at doses of 50 mg, ^337,^ ^344^ 150 mg, ^339,^ ^341^ or 200 mg ^336^ per day. Aydin et al. (1995) ^341^ compared the effect of trazodone to oral testosterone (120 mg/d), hypnosis or placebo. Kurt et al. (1994) compared trazodone to ketanserin and mianserin (antiserotoninergic agents). ^344^ Subjective measures such as self reported questionnaires to address improvement in erection with treatment were used in four trials. ^336,^ ^337,^ ^341,^ ^344^ The outcomes based on RigiScan measurements (i.e. NTP, rigidity) were reported in two trials. ^336,^ ^339^

Harms. In one trial, numerically more patients in the trazodone group reported dry mouth (25.0 percent), drowsiness (18.8 percent), and fatigue (14.6 percent) compared with the placebo group (16.7, 12.5, and 8.3 percent, respectively). ^337^ Another study reported 50 percent more withdrawals due to adverse events in trazodone group versus the placebo group. ^339^ In the trazodone arm of one trail, five patients experienced sedations; no information on adverse events for other groups (i.e., testosterone, hypnosis, and placebo) was reported. ^339^ In a trial comparing the efficacy and harms of trazodone to mianserin, ^344^ two patients (8 percent) withdrew due to adverse events from the mianserin treatment group and two patients (8 percent) in the trazodone group developed serious adverse events (priapism and sedation).

Efficacy. Improvement in erection measured by Index of Sexual Satisfaction was 19 and 24 percent in trazodone and placebo groups, respectively. ^337^ One study reported minor improvement from baseline in trazodone group but the between-group (versus placebo) difference for base rigidity (> 60 percent), nocturnal erection, or morning erection, was not statistically significant. ^336^ For one trial, improved erections were observed in 66, 60, 80, and 39 percent of the patients treated with trazodone, testosterone, hypnosis, and placebo, respectively. ^341^

The proportions of patients with positive response (3 or more successful intercourse attempts during 30 days and rigidity ≥ 30 minutes) at the end of 30 days of treatment with 50 mg trazodone, 20 mg ketanserin, 10 mg mianserin, and placebo were 65.2, 19.1, 31.6, 13.6 percent, respectively. ^344^

Cabergoline versus placebo. Two trials were identified with a total of 452 participants randomly assigned to treatment with cabergoline (n = 225) or placebo (n = 222). ^162,^ ^350^ The trials were conducted in Germany ^350^ and Iran. ^162^ The German study recruited patients with no organic cause of ED. The Iranian study recruited non-responders to previous sildenafil therapy. The mean age of participants was approximately 40 years. Total Jadad scores for the two trials were 3 ^350^ and 5. ^162^ The allocation concealment was unclear in one ^350^ and adequate in the other. ^162^ Both studies were parallel design and placebo controlled. The dose of cabergoline was 0.5 mg per day ^350^ or 0.5–1 mg. ^162^ In both trials, the IIEF was used to measure baseline severity and treatment effect.

Harms. The number of patients with any adverse events was greater in cabergoline group (12.2 percent versus 2.0 percent, p = 0.001). ^162^ Withdrawals due to adverse events were higher in the active arm versus placebo in the study which reported this information (5.9 versus 1.01 percent). ^162^ No information on serious adverse events was reported in any of these trials.

Efficacy. Both trials reported numerically or statistically significant improvements in the results with cabergoline 0.5 mg versus placebo. The German study reported a change of 11.7 in mean scores of erectile domain of IIEF from baseline in comparison to a change of 6.9 in the placebo group. In the Iranian trial, patients improved by 5 points in the Intercourse Satisfaction domain of the IIEF. ^162^ The improvement in Q3 (frequency of penetration), and Q4 (ability to maintain the erection after sexual penetration) was 45.5 and 51.4 percent in the cabergoline arm versus 15 and 20 percent in the placebo arm, respectively. ^162^

Pentoxifylline. Three parallel design studies were included (n = 114, range 18–60). ^340,^ ^343,^ ^345^ Mean age of participants was approximately 60.6 years. The trials were conducted in Turkey ^340^ and US. ^343,^ ^345^ The trial duration ranged from 2 to 3 months.

Total Jadad score ranged from 1 ^340^ to 2. ^343,^ ^345^ Allocation concealment methods were unclear in all three studies.

All three trials were placebo controlled administering 1.2 g/day of pentoxifylline and evaluating subjective measures of improvement in erection. One study also included RigiScan outcomes (i.e., NPT, penile rigidity). ^343^

Pentoxifylline versus Placebo.

Harms. The adverse events including nausea and headaches were transient and mild. ^340^ Harms data was not presented in the other two trials. ^343,^ ^345^

Efficacy. Full erection (sufficient for penetration) was achieved in 10 versus 0 percent ^340^ , and in 78 versus 0 percent ^345^ . One trial ^343^ reported a slight decrease in average percent rigidity after 3 months of treatment with pentoxifylline.

Miscellaneous treatments of ED. Nine trials were identified (n = 449, range: 11–176 participants) that evaluated miscellaneous off label medications for treatment of ED. ^334,^ ^335,^ ^342,^ ^346^ – ^348,^ ^351^ – ^353^ Information on the participants' characteristics, intervention and outcomes is presented in Table 32.

These were five parallel-arm ^334,^ ^346,^ ^348,^ ^351,^ ^353^ and four crossover trials. ^335,^ ^342,^ ^347,^ ^352^ Eight trials were placebo controlled ^334,^ ^335,^ ^342,^ ^346,^ ^348,^ ^351^ – ^353^ and one trial used active medication as comparator. ^347^

Funding sources were reported for only three trials. ^334,^ ^347,^ ^352^ One trial had no source of support. ^335^

Total Jadad scores ranged from 2 ^335,^ ^346,^ ^353^ to 4. ^348^ The methods for allocation concealment were unclear in all studies.

The mean IIEF scores were measured in four trials. ^346^ – ^348,^ ^351^ Other self-reported outcomes related to erection were assessed in four trials ^334,^ ^335,^ ^342,^ ^352^ One trial assessed and reported only rigidity measures (RigiScan). ^353^

Harms. see Table 27.

Table 27 Miscellaneous Treatments: Efficacy and Adverse Events

Author (year) Country | Study Population | Interventions (Dose and duration) | Outcomes | | - Any Event; - Serious Event; - Withdrawals Due to Adverse Event n (%)
Self rated Erection End Points | RigiScan Measures
Mann (2001) Germany | 13 (6/7) men diagnosed with psychogenic ED | - Oral moclobemide, 450 –600 mg/wk; 8 wks; - Placebo | - Clinical Global Impression (GCI), NS between groups | Nocturnal penile response: improvement NS between groups | - 3 (50) vs. 3 (43); - 0; - NR
Piha (2003) Finland | 11 hypertensive men 41–58 years old | - Oral moxonidine, 0. 4–0.6 mg/d; 8 wks; - Oral metoprolol, 100–200 mg/d; 8 wks | - IIEF-5: positive changes in 9/11 (82%) vs. 0, p<0.0002 | NR | NR
Reiter (1998) Austria | 40 (20/20) men with low serum DHEAS (<1.5 μmol/L), and ED unrelated to any other known organic cause | - Oral dehydro-epiandrosterone (DHEA); - Placebo | - IIEF, mean scores in all 5 domains improved in DHAE vs. placebo | NR | - 0; - 0; - 0
Safarinejad (2001) Iran | 44 men 28–55 years old with vasculogenic ED | - Oral isoxsuprine hydrochloride, 60 mg/d; 30 d; - Placebo | - Complete erectile response 8.3% vs. 8.3% (NS) | NR | - 70% vs. 15%; - 1 (2.3) vs. 0; - NR
Sommer (2006) Germany | 18 (NR) men with ED (no etiology reported) | - Oral (BH4) + VSS, 200 or 500 mg; once; - Placebo; once | - NR | Improved duration of >60%: at base 33.1 and 36.1 min; at tip by 29.4 and 33.7 min (200 and 500 mg respectively) | - 3 (17) vs. 1 (5.6); - NR; - NR
Sommer (2006) Italy | 176 (NR) men with DM type II and ED of longer than 6 mo of organic cause | - Oral myoinositol + folic acid Combination, 4g + 400μg; 12 wks; - Placebo; 12 wks | - Mean IIEF-5 change: 8 vs. -1 | NR | - NR
Sommer (2006) Canada | 68 men > 18 years old diagnosed with depressive disorder and ED for longer than 6 mo | - Oral tianeptine, NR; 8 wks; - Placebo; 8 wks | - Patients with full response to treatment: 72.7% vs. 27.9%; - Patients with successful sexual intercourse: 89.4% vs. 50.0% | NR | - 5 (7.4) vs. 1 (1.5); - NR; - NR
Speel (2005) the Netherlands | 59 men with mean age of 60 years old, and atherosclerosis ED | - Oral angiotensin- converting enzyme (ACE), 20 mg/d; 26–46 wks; - Placebo | - IIEF-EF: severity of ED improved in both groups (NS between groups) | NR | - 11 (37) vs. 4 (14); - NR; - NR
Van Ahlen (1995) Germany | 20 men with mean age of 46 y, and idiopathic ED | - Oral Naltrexone (NTX), 25 or 50 mg/ d; 3 mo; - Placebo; 3 mo | - Early morning erections change from baseline 1.39 vs. 0.22 (p<0.05) | NR | - NR

Efficacy. see Table 27.

## Question 3a. What Are the harms of Pharmaceutical Treatments for Male Patients with ED?

## Specific Adverse Events Oral Medications: PDE-5 inhibitors

### Non-Arteritic Anterior Ischemic Optic Neuropathy (NAION)

In total, 194 records were identified that discussed incidence of NAION in men treated with sildenafil. Of these, 10 records reporting on cases of nonarteritic anterior ischemic optic neuropathy (NAION) were included in this review. ^354^ – ^363^ These records were seven case reports ^354^ – ^359,^ ^363^ , two case series ^361,^ ^362^ , and one retrospective cohort study. ^360^ The remaining records not reporting NAION were excluded.

This review identified 19 cases of NAION reported between 1999 and 2007. Findings of the retrospective cohort study, of 4,157,357 veterans 50 years of age or older indicated that men who were prescribed PDE-5 inhibitors over the period of 2 years were not at increased risk of being diagnosed with NAION compared with those who were not prescribed PDE-5 inhibitors (RR = 1.02, 95 percent CI: 0.92–1.12). ^360^ Note that for possible NAION, the corresponding relative risk was statistically significant (RR = 1.34, 95 percent CI: 1.17–1.55). In all cases except for one, ^362^ the administered minimum dose of sildenafil was 50 mg. Overdose of sildenafil was reported in two case reports. ^354,^ ^363^ Further details can be found in Table 28.

Table 28 Nonarteritic Anterior Ischemic Optic Neuropathy (NAION)

Study | Study Design | Subject(s) (number, age, co-morbidities, medical history) | Treatment (type, dose) | Visual Complaint (or diagnosis) | Relative Risk (RR) 95% CI
Akash (2002) | Case report | n = 1 54 years Caucasian None | 100 mg 2–3/week; one time overdose: 200 mg | Blindness in left eye hours post overdose Left combined NAION w+ cilioretinal artery occlusion | NA
Cunningham (2001) | Case report | n = 1 42 years Depression | 50 mg/d; 3 doses | Blurred vision post 2^nd^ and 3^rd^ dosing NAION | NA
Dheer (2002) | Case report | n = 1 48 years None | 100 mg/d; two doses | Blue flashes and blurring vision in both eyes NAION | NA
Egan (2000) | Case report | n = 1 52 years Transurethral resection for prostate cancer | 50 mg; single dose | Bilateral blue lightning bolts and blurry vision within 1 hr post dosing NAION | NA
Gedik (2006) | Case report | n = 1 36 years NR | 100 mg; two separate dosing 4 months apart | Blurred vision deteriorated to light perception in both dosing cases NAION | NA
Grugn (2004) | Case report | n = 1 69 years (only case reported to date in Scandinavia) | 50 mg (single dose) | Abnormal vision in right eye NAION | NA
Margo (2007) | Retrospective cohort | n = 479,489 Veterans ≥50 years; documented PDE-5 inhibitor use | 100 mg in 99.4% of pts | NR Diagnosed NAION: n = 442 (<1%) Possible NAION: n = 228 (<1%) | RR for diagnosed NAION = 1.02 (95% CI 0.92–1.12)* RR for possible NAION = 1.34 (95% CI: 1.17–1.55)
Pomeranz (2002) | Case series | n = 5 42–69 years, elevated lipids, smoking, diabetes, coronary artery disease, diagnosis of NAION (n = 1) | 50–100 mg | Loss of vision in the affected eye within min to hrs post dosing NAION | NA
Pomeranz (2005) | Case series | n = 7 50–69 years, hypertension, diabetes, elevated cholesterol, or hyperlipidemia | 25–50 mg (dosing regiment ranged from single dose to sporadic use over several years) | Vision loss [unilateral (n=6), bilateral (n=1)] NAION | NA
Sinha (2004) | Case report | n = 1 61 years, smoking | 200 mg at once (usual dose of 100 mg) | Loss of vision in right eye Possible NAION | NA

* Relative risk was calculated as ratio of risks in men exposed to PDE-5 inhibitors those unexposed.

## Injection Treatments

### Penile Fibrosis (Non-randomized studies: observational studies and clinical trials)

In total, 20 non-randomized studies (retrospective observational cohort, and clinical trials) reporting the absence or presence of penile fibrosis in long-term followup (at least 6 months) met the eligibility criteria for inclusion in the review (in 20 publications). ^364^ – ^383^ Of these, 13 were clinical trials of prospective design ^364^ – ^366,^ ^368^ – ^371,^ ^376^ – ^378,^ ^380,^ ^381,^ ^383^ and seven were retrospective cohort studies. ^367,^ ^372^ – ^375,^ ^379,^ ^382^

The number of subjects included in the 20 studies ranged from 10 ^370^ to 1089. ^374^ The majority of the study subjects were middle aged (mean age range: 50–62 years). Four trials included special population subgroups such as patients diagnosed with diabetes, ^366,^ ^369^ multiple sclerosis, ^381^ and prostate cancer followed by prostatectomy. ^367^ One study evaluated ICI therapy in geriatric men (age >65 years). ^382^

Prostaglandin (PGE_1_) alone or in combination with other vasoactive agents (papaverine and/or phentolamine) was evaluated in 15 studies. ^364^ – ^378^ Papaverine alone or in combination with phentolamine (or verapamil) was evaluated in 13 studies. ^366,^ ^367,^ ^369,^ ^371,^ ^373,^ ^374,^ ^376,^ ^377,^ ^379^ – ^383^ The duration of treatment ranged from 3 months ^368^ to 10 years. ^366^ In the majority of studies, the approximate frequency of PGE_1_ injections was up to twice per week with a mean dose of 20 μg or lower. ^365,^ ^370,^ ^372,^ ^375,^ ^378^

Of the 20 studies, five explicitly reported the absence of new cases of fibrosis. ^367,^ ^368,^ ^370,^ ^371,^ ^378^ and six studies reported the incidence of fibrosis to be under 5 percent. ^373,^ ^376,^ ^377,^ ^379^ – ^382^

The proportion of patients with fibrosis in studies that used PGE_1_ alone after at least one year of followup ranged from 4.4 percent ^365^ to 23.3 percent. ^372^ In two of these studies no cases of fibrosis were observed. ^370,^ ^378^ For example, one retrospective cohort study in Australian men ^372^ reported an incidence of fibrosis in 57 of the 245 patients (23.3 percent) who had been treated with PGE_1_ 2–60μg (mean 13μg) for 2 years on average. The total amount of PGE_1_ (p = 0.0062) and the total number of injections (p = 0.0032) over the whole treatment period were statistically significantly greater in the men with fibrosis. However, there were no significant differences between the men who developed fibrosis and men who did not with regard to duration of followup, injection frequency, or dose per injection. ^372^ In contrast, in another prospective trial, ^365^ only three (4.4 percent) of the 68 PGE1-treated patients (the mean PGE1 dose: 11.6μg) developed fibrosis after at least one year of followup. Of these three patients, only one patient injected PGE_1_ more frequently and at a higher dose (20–60μg every 2–3 days) than it was prescribed (one injection 10–20μg per 5–7 days).

The largest study that evaluated and compared adverse events in patients receiving ICI injections with different medications was a retrospective U.S. study of 1089 patients who had received either 5–10μg PGE_1_, trimix (1.47μg PGE_1_ plus 4.41 mg papaverine plus 0.5 mg phentolamine), papaverine plus phentolamine, or 10μg PGE_1_ plus 30 mg papaverine for up to 80 months. This study investigated reasons for attrition in each treatment group. Of the subjects discontinuing the treatment, penile scarring/nodules was the reason for study withdrawal in 23 percent (6/26), 11 percent (4/36), and 10 percent (8/75) of the subjects receiving triple therapy (PGE_1_/papaverine/ phentolamine), combination papaverine and phentolamine therapy, and PGE_1_ monotherapy, respectively. None of the patients receiving the combination of PGE1 with papaverine developed penile scarring/nodules. ^374^ In a controlled trial conducted in Taiwan, ^377^ 51 patients with ED (mean age: 58 years) received self-injections either with 20μg PGE_1_ or 30 mg papaverine for about 12 months (range: 1.5–30.5 months). Two patients (3.9 percent) developed fibrosis after 60 mg papaverine injections. No cases of fibrosis were observed in patients after PGE_1_ injections. ^377^ Similarly, in a trial conducted in Turkey, ^376^ 69 patients with ED (mean age: 52.6 years) were divided to receive injections either with 10μg PGE_1_ (n = 13 patients) or 15–30 mg papaverine (n = 56 patients) for approximately 12 months. Two patients (3.6 percent) in the papaverine group developed fibrosis versus none in the PGE_1_ group. In a retrospective North American cohort study, ^373^ 108 ED patients received self-injections with either 30 mg papaverine (n = 21 patients), the combination of 25 mg papaverine with 0.83 mg phentolamine (n = 77), or PGE_1_ (n = 2 patients) were followed-up for 5 years. Only one of the 108 subjects developed fibrosis (the assigned intervention not reported). (Table 29)

Table 29 Penile Fibrosis in Studies of Intracavernosal Injection (Non-randomized)

Study | Study Design | Patients | Treatment(s) | Treatment Duration | Fibrosis % (n/N) by Treatment Group
Perimenis 2006 | Clinical trial | 38 Greek men Mean age 56.4 (range 42–62) years With diabetes mellitus (DM) (type I and II) | 1 Prostaglandin (PGE_1_) 5–20 μg; 2 Papaverine (PAP) ≥8 mg; 3 PGE_1_ + PAP 20 μg/ 8 mg | 10 years | 13.2% (5/38)
Althof 1991 | Clinical trial | 42 American men, mean age 54.4 years | PAP + phentolamine, NR | 12 months | 26%
Canale 1996 | Clinical trial | 68 Italian men, mean age 50.5 (22–70) years | PGE_1,_20 μg/ml /wk (20–60 μg/2–3 d in one case) | > 12 months | 4.4% (3/68)
Porst 1998 | Clinical trial | 162 European men, mean age 54 (22–70) years | PGE_1_, NR | 1– 4 y | 11.7% (19/162) 1^st^ y: 6.8% 2^nd^ y: 2.5% 3^rd^ y: 7.3% 4^th^ y: 1.7%
Claro 2001 | Retrospective cohort | 168 Brazilian men, median age 61 (43–78) years, had undergone prostatectomy for localized prostate cancer | 1 PAP + Phentolamine (PHEN) + PGE_1_ 22.6 mg / 1.34 mg/ 13.4 mg | NR | 0%
Lepore 2001 | Clinical trial | 52 Italian men, mean age 56.7 (range 35–74) years With diabetes | 1 PGE_1_ NR; 2 Sildenafil | 3 months | 0%
Perimenis 2001 | Clinical trial | 40 Greek men 18 diabetic and 22 non-diabetic controls Mean age 55.6 (48–64) | 1 PGE_1_ 5–20 μg; 2 PAP 8–16 mg; 3 PGE_1_ + PAP 20 μg/ 8–16 mg | 7 years | 17.5% (7/40) One non-diabetic control developed early Peyronie's plaque leading to study withdrawal
Wespes 2000 | Clinical trial | 10 Belgian men, mean age 56.5 (46–69) years | 1. PGE_1_ 6–20 ug | NR | 0%
Shmueli 1999 | Clinical trial | 452 Israeli men, mean age 59.5 (26–85) years | Protocol I: PAP + PHEN 6–25 mg/ 0.05–1.5 mg. Patients who failed received Protocol II: PGE_1_10–25 μg. Patients who failed received Protocol III: PAP + Phentolamine + PGE1 Patients who failed received Protocol VI: PAP + Phentolamine + PGE1+ atropine 0.02–0.06 mg | 6 months | 0% Small nodules Protocol I: 0.6% (3/452) Protocol II: 2% (3/147) Protocol III: 3.5% (3/86) Protocol IV: 9.7% (3/31)
Chew 1997 | Retrospective cohort | 245 Australian men, mean age 62 (21–79) years, hypertension (22.8%), DM (8.5%) | 1 PGE_1_2–60 μg (mean 13 μg) | 2.1 years (up to 86 months) | 23.3% (57/245)
Sundaram 1997 | Retrospective cohort | 160 American men Age not reported | 1 PAP 30 mg; 2 PAP + PHEN 25 mg + 0.83 mg; 3 PGE_1_ NR (alternative therapy) | 1–5 years | <1% (1 patient)
Gupta 1997 | Retrospective cohort | 1089 American men, mean age 62 (21–94) years | 1 PGE_1_5–10 μg; 2 TRIMIX 4.41 mg/ 0.5 mg/ 1.47 μg; 3 PGE_1_ + PAP 5–10 μg/ 30 mg; 4 PAP + PHEN 30 mg/ 0.5 mg | Up to 80 months | Penile scarring/nodules in patients discontinuing therapy; 1 PGE_1_10.7% (8/75); 2 TRIMIX 23.1% (6/26); 3 PAP + PHEN 11.1% (4/36)
Flynn 1996 | Retrospective cohort | 126 British men, mean age 57 (27–77) years, 40% had co-morbidities | 1 PAP NR; 2 PAP + PHEN NR | 3.9 years | <1% (1 subject)
Chen 1996 | Retrospective cohort | 92 American men, mean age 58.6 (32–78) years, 67% had co-morbidities | 1 PGE_1_ initial dose <10 μg/ml in most cases | 1–56 months | 16.3% (15/92)
Bolayir 1994 | Clinical trial | 40 Cypriot men, age range 40–75 years | 1 PAP + Verapamil 20–35 mg/5 mg | 1 year | 2.5% (1/40)
Hattat 1994 | Clinical trial | 69 Turkish men, mean age 52.6 (31–71) years | 1 PGE_1_ NR; 2 PAP NR | 13.6 months | 3.6% (2/56) PAP 0 (0/13) PGE_1_
Betts 1994 | Clinical trial | 46 British men, mean age 39 (26–58) with multiple sclerosis | 1 PAP 10–80 mg | NR | 2.2% (1/46)
Chiang 1992 | Clinical trial | 51Taiwanese men, mean age 58.3 (29–79) years | 1 PGE_1_ 5–40 μg; 2 PAP 15–60 mg | 1 year | 3.9% (2/51)
Kerfoot 1991 | Retrospective cohort | 119 American men Group 1 (n = 65): Geriatric (>65), mean age 70 years Group 2 (n = 54): younger, mean age 47 | 1 PAP + PHEN 30 mg / 1.0 mg (titrated up to 1.5 if no response) | > 6 months | 2.5% (3/119)
Schramek 1990 | Clinical trial | 149 Austrian men, Mean age 56.5 (25–76) years | 1 PGE1 10–40 μg | NR | 0%