# Executive Summary

## Introduction

Erectile dysfunction (ED) is a complex condition involving psychosocial and biological factors. It is defined as the persistent inability to achieve or maintain penile erection sufficient for satisfactory sexual performance. ED is a common disorder of male sexual function, affecting all age groups with a considerable impact on quality of life.

Oral phosphodiesterase type 5 (PDE-5) inhibitors are the first-line treatment options offered to patients with ED. This systematic review of the recent evidence on clinical benefits and harms associated with different pharmaceutical treatments used in the management of male ED is to clarify uncertainties in the field, as well as to identify existing knowledge gaps and directions for future research.

The University of Ottawa Evidence-based Practice Center (UO-EPC) reviewed and synthesized the published literature on the pharmaceutical treatment of male ED. This review addressed the following key questions (KQ):

KQ 1: What is the clinical utility of routine blood tests—testosterone, prolactin, luteinizing hormone (LH), follicle stimulating hormone (FSH)—in identifying and affecting therapeutic outcomes for treatable causes of ED?

KQ 2: What are the benefits of pharmaceutical treatments for patients with ED? How do patient-specific characteristics (e.g. specific symptoms, age, comorbid conditions) affect prognosis and treatment success for ED patients? Does likelihood of treatment success vary by underlying cause of ED?

KQ 3: What are the harms of pharmaceutical treatments for ED? What is the evidence on specific harms such as nonarteritic ischemic optic neuropathy (NAION) and penile fibrosis of pharmaceutical treatments for ED?

## Methods

### Literature Search

A comprehensive search was conducted in MEDLINE® (1966-2006), Cochrane CENTRAL (2006-2007), EMBASE (1980-2007), PsycINFO® (1985-2007), and SCOPUS™ (2006). The search was limited to English language reports published in 1990 or later. MEDLINE® (1966-2007) and EMBASE (1980-2007) were searched for reports of visual problems associated with the use of sildenafil, and MEDLINE® (1950-2007) and EMBASE (1980-2007) were searched for reports regarding fibrosis associated with penile injections.

### Study Selection

English-language primary studies examining pharmaceutical treatments of ED were eligible for inclusion. Reviews, editorials, commentaries and letters were excluded for all questions except Q3. The reasons for exclusion were noted in the QUOROM flow diagram. Only randomized controlled trials (RCTs) were eligible for evidence on efficacy, whereas non-randomized controlled trials and observational studies were included to examine harms associated with ED treatments. Two independent reviewers performed full-text screening; discrepancies were resolved by consensus.

### Data Extraction and Assessment of Study and Reporting Quality

Two reviewers independently abstracted relevant information from included studies using a data abstraction form. One reviewer completed the primary extraction, which was then verified by a second reviewer. Abstracted data included study, population, and treatment characteristics (type, mode, dose, route of administration); efficacy outcomes such as absolute mean endpoint/change (from baseline) in scores for the International Index of Erectile Function (IIEF) “Erectile Function (EF) domain,” Sexual Encounter Profile (SEP) Q-2/3, and the proportion of patients with improved erection measured with Global Assessment Question 1 (GAQ-1)(see Appendix H). We abstracted information on any and most frequently encountered specific adverse events, withdrawals due to adverse events, and serious adverse events. Additionally, for Q1, prevalence rates of hypogonadism and hyperprolactinemia in ED populations were ascertained and abstracted. The Jadad scale and Schulz questionnaire were used to assess the study and reporting quality and the adequacy of allocation concealment in RCTs.

### Synthesis of the Evidence

The outcomes for each study were summarized qualitatively. The information pertaining to sample size and demographics, setting, funding source, treatment (dose and duration), comparator characteristics, study quality, and confounders was recorded and summarized in the text and summary tables. The decision to statistically pool results of individual studies was based on clinical and methodological judgement. If relevant numerical data (e.g. arm-specific mean endpoint/change in score, standard deviation, and standard error) were not reported adequately, we attempted to calculate the needed parameters. For dichotomous and continuous effect measures, pooled estimates of relative risk (RR) and weighted mean differences (WMD) with corresponding 95 percent confidence intervals (95 percent CI) were generated using the DerSimonian and Laird random effects model. The degree of statistical heterogeneity was evaluated using a chi-square test and the I^2^ statistic.

A series of subgroup analyses was also performed to explore the consistency of the results. Publication bias was assessed by means of funnel plots.

## Results

### KQ 1: What is the clinical utility of routine blood tests (testosterone, prolactin, LH, FSH) in identifying and affecting therapeutic outcomes for treatable causes of ED?

The prevalence of hypogonadism varied widely across the studies (12.5 to 25.32 percent). This variation reflected differences in diagnostic criteria for hypogonadism, testosterone measurement methods (e.g. serum total, bioavailable or free levels) and concurrent conditions present across the studies. The prevalence of hypogonadism was higher in men ≥ 50 years versus men < 50 years of age. The results of several studies indicated that ED patients with decreased libido, testicular damage/abnormality, arterial disease, obesity, hyperlipidemia, diabetes, or hypothalamic abnormalities were more likely to have hypogonadism than those presenting without these factors.

The prevalence of hyperprolactinemia varied from 1.42 to 14.3 percent. One Egyptian study in elderly and obese men reported a prevalence of 32 percent. In one of the 9 studies reporting abnormal levels of LH/FSH, about 44 percent of the hypogonadal men had low LH/FSH levels (<13 IU/mL). The prevalence of high LH/FSH levels across three studies varied from 1.03 to 5.79 percent.

### KQ 2: What are the benefits of pharmaceutical treatments for patients with ED?

### How do patient-specific characteristics (e.g. specific symptoms, comorbid conditions) affect prognosis/treatment success for ED patients?

### Does likelihood of treatment success vary by underlying cause of ED?

In total, 126 RCTs evaluating clinical benefits and harms of oral PDE-5 inhibitors (i.e., sildenafil, tadalafil, and vardenafil) in ED patients were included in the review. Patients receiving PDE-5 inhibitors (regardless of dose/dosing regimen) experienced statistically significant and clinically relevant improvements in erectile functioning (mean total IIEF-“EF domain” and IIEF-Q3/Q4 scores, mean SEP-Q2/Q3 scores, improved erection measured by GAQ-Q1) and satisfaction (mean total IIEF-“Intercourse Satisfaction” and “Overall Satisfaction” domains, Erectile Dysfunction Index of Treatment Satisfaction scores) compared with those receiving placebo. The meta-analyses indicated that the use of sildenafil was associated with statistically significant improvements in penile penetration (IIEF-Q3 mean difference: 1.46, 95 percent CI: 1.26–1.65) and improved erection (RR = 2.61, 95 percent CI: 2.34–2.91) compared with placebo. The clinical benefit associated with the use of PDE-5 inhibitors relative to placebo was also observed in clinically distinct subgroups of patients (e.g. diabetes, depression, prostate cancer).

Patients with mild or moderate ED at baseline (IIEF score 11–25) achieved higher mean IIEF-“EF domain” or IIEF-Q3/Q4 scores compared with those with severe ED. The mean scores for IIEF and SEP, improvement in erection, and mean duration of penile rigidity (>60 percent) tended to increase with higher doses of sildenafil (25 mg versus 50 mg versus 100 mg) and vardenafil (5 mg versus 10 mg versus 20 mg).

Results from four head-to-head trials comparing sildenafil, vardenafil, and tadalafil for improvements in erectile function were inconclusive. The between-arm differences in the mean IIEF-EF scores were either statistically non-significant or significant but of small magnitude. In all 4 trials, higher proportion of patients preferred tadalafil to sildenafil or vardenafil. The mean time (in hours) between dosing and sexual attempt was longer for tadalafil compared with sildenafil (5.6 versus 2.7, p < 0.001) and a greater proportion of tadalafil-treated men had one or more successful intercourse attempt 12 or more hours post-dose versus sildenafil-treated men (55 versus 29 percent, p < 0.001).

The administration of intracavernosal injections (ICI) of alprostadil improved erections more often than no treatment, placebo, papaverine, or phentolamine alone, and at least as often as trimix (prostaglandin E_1_ plus papaverine plus phentolamine). In three trials, the use of intraurethral suppositories containing alprostadil was shown to be more effective than placebo.

There were 18 RCTs evaluating the efficacy of hormonal treatment with testosterone (in oral, injection, gel, patch, and cream forms) predominantly in hypogonadal patients with or without ED as a main complaint. In only one of four small trials, the intramuscular injection of testosterone improved erectile function compared with placebo. Gel testosterone (50 mg and 100 mg doses) was found to have increased sexual intercourse frequency compared with placebo or patch testosterone.

Two RCTs compared testosterone treatment (alone or combined) with PDE-5 inhibitors in hypogonadal patients with ED that was refractory to prior sildenafil therapy (this was also relevant to Question 1). In both trials, patients treated with the combination of testosterone (either patch 5 mg/d or gel 1 percent) and 100 mg sildenafil had statistically significantly greater IIEF scores compared with those treated with sildenafil alone (endpoint: 21.8 versus 14.4, p <0.05 and mean change: 4.4 versus 2.1, p = 0.029).

### KQ 3. What are the harms of pharmaceutical treatments for patients with ED?

### What is the evidence on specific harms such as nonarteritic ischemic optic neuropathy (NAION) and penile fibrosis related to pharmaceutical treatments in patients with ED?

All-cause adverse events were more frequent in patients treated with PDE-5 inhibitors compared with those treated with placebo. In particular, meta-analyses demonstrated that patients receiving sildenafil (any dose) were at higher risk of any adverse (RR = 1.51, 95 percent CI: 1.32–1.72). The 12-week use of 20 mg tadalafil was also associated with an increased risk of any adverse events (RR = 1.61, 95 percent CI: 1.37–1.89). The most common adverse events in PDE-5 inhibitor-treated patients were headache, flushing, dyspepsia, and rhinitis. The use of both sildenafil and vardenafil was associated with an increased risk of headache, dyspepsia, or flushing compared with placebo. Patients treated with sildenafil had an increased risk of visual disturbances (RR = 3.66, 95 percent CI: 2.27–5.92).

Serious adverse events were not statistically different between PDE-5 inhibitor and placebo groups. For example, patients treated with vardenafil experienced a statistically non-significant 34 percent increase in risk of serious adverse events (RR = 1.34, 95 percent CI: 0.76–2.36). Although the rate of withdrawals due to adverse events was slightly increased in patients receiving vardenafil versus those on placebo, the pooled RR estimate did not reach the level of statistical significance (RR = 1.29, 95 percent CI: 0.78–2.13).

The incidence of adverse events increased with the dose of PDE-5 inhibitors. Meta-analyses demonstrated a statistically significant increase in the risk of any adverse events between patients receiving 20 mg versus 10 mg of either tadalafil (RR = 1.21, 95 percent CI: 1.05–1.38) or vardenafil (RR = 1.15, 95 percent CI: 1.06–1.25). The pooled RR estimates for specific events in sildenafil treated patients were: flushing (50 mg versus 25 mg; RR = 1.65, 95 percent CI: 1.13–2.42), headache (100 mg versus 50 mg; RR = 1.31, 95 percent CI: 0.93–1.84), and visual disturbances (100 mg versus 50 mg; RR = 4.18, 95 percent CI: 0.44–39.54). The differences in the incidence of any adverse events between treatment and placebo groups did not vary significantly among four head-to-head trials with patients treated with sildenafil, tadalafil, or vardenafil.

Penile pain or priapism was more frequent in patients treated with alprostadil injections compared with those who received placebo. Patients who received a testosterone patch had a higher rate of skin reactions at the application site compared with those who received the placebo. One trial reported prostate cancer in two patients treated with a testosterone patch. The use of gel testosterone did not show a dose-related increase in adverse events.

To ascertain the incidence of NAION in subjects using PDE-5 inhibitors, this review identified 19 case reports and one large retrospective cohort study of U.S. veterans aged 50 years or older. In almost all case reports, the minimum dose of sildenafil was 50 mg. The risk of NAION in veterans prescribed PDE-5 inhibitors for 2 years was not increased compared with those who were not prescribed PDE-5 inhibitors (RR = 1.02, 95 percent CI: 0.92–1.12). The long-term data on fibrosis amongst penile injection users (e.g. PGE_1_, papaverine, and/or phentolamine) was obtained from 13 reports of non-randomized controlled trials and 7 retrospective cohort studies. In these studies, the proportion of patients with fibrosis amongst those receiving PGE_1_ injections for at least one year, ranged from 4.4 to 23.3 percent. Clinical diversity (i.e., populations, intervention dose/duration/frequency, injection type, duration of followup), scarce data, confounding, and lack of appropriate comparator precluded a meaningful between-group comparison of the incidence of fibrosis.

### Discussion and Future Research

The utility of routine endocrinological blood tests to identify treatable causes of ED and to improve therapeutic outcomes was unclear due to study heterogeneity. Prevalence of endocrinopathies, patient characteristics, diagnostic criteria, age distribution, laboratory methods (cut-off values, total, free, bioavailable hormonal levels), and/or study methodology varied widely. Factors such as obesity, decreased libido, testicular damage/abnormality, arterial disease, and/or insulin resistance may be predictive of hypogonadism in patients with ED. Studies to measure the prevalence of endocrinopathies and RCTs comparing the efficacy of testosterone relative to PDE-5 inhibitors would further clarify the clinical utility and cost-effectiveness of routine blood tests. The standardization of blood tests would facilitate this process. Furthermore, determination of subgroups (or risk factors) of ED patients with increased risk of hypogonadism is warranted. Additionally, clinicians would need to direct their efforts towards correctly identifying and treating underlying causes of ED, including hormonal disorders.

The efficacy of PDE-5 inhibitors was evaluated using clinically relevant and validated outcome measures. These measures are based on patient responses, and therefore are subjective in nature. Patients preferred tadalafil over sildenafil or vardenafil in four head-to-head trials in part due to the longer duration of the action of tadalafil compared with the other two agents. The evidence regarding the incidence of serious adverse events is not conclusive for several reasons, including poor reporting practices and the use of different definitions of serious adverse events. Some reports indicated only the most frequently encountered or treatment-related adverse events, the ascertainment of which may be prone to subjective judgment. In open label trials, patients or investigators may have over- or underreported the incidence of adverse events because of their knowledge of the assigned treatment. Moreover disease-specific complications in patients with comorbidities or disorders known to cause ED could have been overlooked. The exclusion criteria reported for many PDE-5 inhibitor trials mean that results may not be readily applicable to patients diagnosed with major chronic disorders (e.g. cancer, CVD, diabetes, psychiatric disorders, or hepatic or renal diseases) or those who had undergone surgery (e.g. prostatectomy).

The comparative evidence for the efficacy and harms associated with subcutaneous injections, sublingual, topical treatments, or intra-urethral suppositories was limited and inconsistent. One common limitation of the trials evaluating these therapies was that clinically relevant efficacy outcomes were not reported. Differences in patient inclusion criteria (e.g. not all trials were comprised exclusively of ED patients), methods of evaluation, interventions (e.g. different formulations/modes of application), or outcome definitions could explain some of the discrepancies in results across the studies evaluating the efficacy of testosterone.

Future efforts are needed to improve the quality of reporting of primary studies. In the presence of comorbidities or causes underlying ED, the comparison of cause-specific therapies (i.e. targeting underlying causes of ED) to symptomatic treatments (e.g. PDE-5 inhibitors, injections, hormonal treatments) in terms of efficacy and safety profiles is warranted. New, well-designed trials are warranted to examine long-term clinically relevant treatment outcomes (6 months or longer) in both broadly defined and clinically homogeneous subgroups of ED patients. There is also a need for head-to-head trials to compare various PDE-5 inhibitors with one another as well as trials comparing PDE-5 inhibitors with other symptomatic treatments for ED (e.g. oral, injected, and topical treatments).

Viewed in perspective, this report represents a striking example of a situation that reviewers of medical effectiveness research encounter often: a field of information in which one corner is intensively cultivated and other areas lie fallow. Erectile dysfunction can be treated at present by two main classes of drugs, phosphodiesterase type-5 inhibitors and/or androgens. This review finds a dearth of credible evaluations of androgens as treatment for ED — clarifying neither short-term effectiveness nor long-term outcomes (positive or negative). In light of the growing popularity of androgen supplementation for a variety of indications in aging men, and in the context of complicated and controversial findings of the far more extensive studies of hormone replacement therapy in women, this gap in our research base is especially noteworthy. For PDE-5 inhibitors, in contrast, an impressive amount of clinical trial evidence is available, demonstrating that these drugs do have a real effect. The impetus for much of this research arose from the desire to get PDE-5 inhibitors approved by the FDA. For instance, nearly three-quarters of the PDE-5 inhibitor trials in this review were funded by pharmaceutical companies.

Even for the PDE-5 inhibitors, important aspects remain inadequately explored. The effects observed in the controlled trials mostly denote differences of small magnitude in self-reported subjective judgments of function on a standardized questionnaire (e.g., the difference between “a few times” and “sometimes,” or between “sometimes” and “most times”). Because of the randomization and the large number of subjects, the evidence is convincing that there is some therapeutic effect; the extent to which these “real” effects are great enough to be clinically meaningful is not as clear, and that is a separate question which this review does not address. Moreover, although short-term side-effects of the PDE-5 inhibitors have been investigated (as the FDA requires), very few studies have tried to investigate long-term side-effects or long-term outcomes - such as persistence or attenuation of effectiveness with continued use.

In summary, while research pertaining to short-term effects of the PGE-5 inhibitors is abundant, comparable studies on androgens and information on long-term treatment outcomes for either class are sparse. The skewed concentration of research on the effectiveness of treatments for ED reflects the short-term focus of the new-drug approval process. The value of information might be enhanced by new sources of financial support for research and/or a change in regulatory requirements that would encourage broader comparisons and a longer time horizon.

### Conclusions

The evidence comparing cause-specific therapies with symptomatic treatments (e.g. PDE-5 inhibitors, injections, and hormonal treatments) for management of ED is lacking. Due to the complexity of causative and comorbid factors, more studies are needed to clarify the best treatment management options for various subgroups of patients with ED (e.g. endocrinopathies, concurrent clinical conditions). There is also a need for trials comparing PDE-5 inhibitors with other treatments for ED (e.g. oral, injected and topical). Long-term effects of ED treatments in RCTs have not been adequately explored. To clarify and determine the clinical utility of routine hormonal blood tests in ED patients, studies are needed in representative populations, with comparable diagnostic criteria and types of tests for hormonal disorders.