# Acknowledgments

The authors would like to thank numerous individuals for their support of the present project. Investigators thank Nathalie Lapierre, Gloria Baker, and Dorothey Ann Curran for their assistance with screening articles and helping with data abstraction; David Mackie and Mary Ocampo for helping with the evidence tables and appendices; and Tanya Horsley and Kasey Parker, both of whom helped to coordinate the process. Investigators would also like to thank Anne Marie Todkill, who assisted in the editing of the report.