# References

1 Institute of Medicine. Preventing Childhood Obesity: Health in the Balance. Washington, D.C.: National Academies Press; 2005.
2 National Institute for Health and Clinical Excellence. Obesity: Guidance on the prevention, identification, assessment and management of overweight and obesity in adults and children. Report No. 43. MidCity Place, London, National Institute for Health and Clinical Excellence. 2006.
3 Institute of Medicine. Progress in Preventing Childhood Obesity: Focus on Industry. Washington, D.C.: National Academies Press; 2006.
4 Center for Disease Control and Prevention. 2000 CDC Growth Charts: United States. Center for Disease Control and Prevention. 2000.
5 Barlow SE. Expert Committee. Expert committee recommendations regarding the prevention, assessment, and treatment of child and adolescent overweight and obesity: Summary report. Pediatrics. Dec. 2007;120(4):Suppl 164-92. [pmid: 18055651].
6 Mei Z, Grummer-Strawn LM, Pietrobelli A, et al. Validity of body mass index compared with other body-composition screening indexes for the assessment of body fatness in children and adolescents. Am J Clin Nutr. 2002;75:978-85. [pmid: 12036802].
7 Reilly JJ, Methven E, McDowell ZC, et al. Health consequences of obesity. Arch Dis Child. 2003;88:748-52. [pmid: 12937090]. [pmcid: 1719633].
8 Must A, Jacques PF, Dallal GE, et al. Long-term morbidity and mortality of overweight adolescents. A follow-up of the Harvard Growth Study of 1922 to 1935. N Engl J Med. 1992;327:1350-55. [pmid: 1406836].
9 Must A, Strauss RS. Risks and consequences of childhood and adolescent obesity. Int J Obes Relat Metab Disord. 1999;23(Suppl 2):S2-11. [pmid: 10340798].
10 Freedman DS, Mei Z, Srinivasan SR, et al. Cardiovascular risk factors and excess adiposity among overweight children and adolescents: The Bogalusa Heart Study. J Pediatr. 2007;150:12-17. [pmid: 17188605].
11 Spear BA, Barlow SE, Ervin C, et al. Recommendations for treatment of child and adolescent overweight and obesity. Pediatrics. 2007;120(Suppl 4):S254-88. [pmid: 18055654].
12 Barlow SE, Bobra SR, Elliott MB, et al. Recognition of childhood overweight during health supervision visits: Does BMI help pediatricians?. Obesity. 2007;15(1):225-32. [pmid: 17228051].
13 Wang Y, Beydoun MA. The obesity epidemic in the United States—gender, age, socioeconomic, racial/ethnic, and geographic characteristics: A systematic review and meta-regression analysis. Epidemiol Rev. 2007;29:6-28. [pmid: 17510091].
14 Ogden CL, Carroll MD, Curtin LR, et al. Prevalence of overweight and obesity in the United States, 1999-2004. JAMA. 2006;295:1549-55. [pmid: 16595758].
15 Hedley AA, Ogden CL, Johnson CL, et al. Prevalence of overweight and obesity among US children, adolescents, and adults, 1999-2002. JAMA. 2004;291:2847-50. [pmid: 15199035].
16 Wang Y, Lobstein T. Worldwide trends in childhood overweight and obesity. Int J Pediatr Obes. 2006;1:11-25. [pmid: 17902211].
17 Harris KM, Gordon-Larsen P, Chantala K, et al. Longitudinal trends in race/ethnic disparities in leading health indicators from adolescence to young adulthood. Archives of Pediatrics & Adolescent Medicine. 2006;160(1):74-81. [pmid: 16389215].
18 Freedman DS, Khan LK, Serdula MK, et al. Racial differences in the tracking of childhood BMI to adulthood. Obes Res. 2005;13:928-35. [pmid: 15919847].
19 Freedman DS, Ogden CL, Flegal KM, et al. Childhood overweight and family income. MedGenMed. May. 2007;9:26. [pmid: 17955082].
20 Davison KK, Birch LL. Child and parent characteristics as predictors of change in girls' body mass index. Int J Obes Relat Metab Disord. 2001;25:1834-42. [pmid: 11781765]. [pmcid: 2530937].
21 Garn SM, Clark DC. Trends in fatness and the origins of obesity Ad Hoc Committee to Review the Ten-State Nutrition Survey. Pediatrics. 1976;57:443-56. [pmid: 1264536].
22 Gordon-Larsen P, Adair LS, Suchindran CM. Maternal obesity is associated with younger age at obesity onset in U.S. adolescent offspring followed into adulthood. Obesity. 2007;15:2790-96. [pmid: 18070770].
23 Tait AR, Voepel-Lewis T, Burke C, et al. Incidence and risk factors for perioperative adverse respiratory events in children who are obese. Anesthesiology. 2008;108:375-80. [pmid: 18292674].
24 Erermis S, Cetin N, Tamar M, et al. Is obesity a risk factor for psychopathology among adolescents?. Pediatr Int. 2004;46:296-301. [pmid: 15151546].
25 Strauss RS. Childhood obesity and self-esteem. Am J Clin Nutr. Jan. 2000;105(1):e15.
26 Schwimmer JB, Burwinkle TM, Varni JW. Health-related quality of life of severely obese children and adolescents. JAMA. 2003;289:1813-19. [pmid: 12684360].
27 Freedman DS, Khan LK, Serdula MK, et al. The relation of childhood BMI to adult adiposity: The Bogalusa Heart Study. Am J Clin Nutr. 2005;115:22-27.
28 Reeves GK, Pirie K, Beral V, et al. Cancer incidence and mortality in relation to body mass index in the Million Women Study: Cohort study. BMJ. Dec. 2007;335(7630):1134. [pmid: 17986716]. [pmcid: 2099519].
29 Renehan AG, Tyson M, Egger M, et al. Body-mass index and incidence of cancer: a systematic review and meta-analysis of prospective observational studies. Lancet. 2008;371:569-78. [pmid: 18280327].
30 Flegal KM, Graubard BI, Williamson DF, et al. Cause-specific excess deaths associated with underweight, overweight, and obesity. JAMA. 2007;298:2028-37. [pmid: 17986696].
31 Whitlock EP, Williams SB, Gold R, et al., Screening and interventions for childhood overweight: Evidence synthesis number 36. AHRQ Publication No. 05-0582-B-EF. Rockville, MD, Agency for Healthcare Research and Quality. 2005.
32 Krebs NF, Himes JH, Jacobson D, et al. Assessment of child and adolescent overweight and obesity. Am J Clin Nutr. 2007;120(Suppl 4):S193-S228.
33 American Dietetic Association. Position of the American Dietetic Association: Individual-, family-, school-, and community-based interventions for pediatric overweight. J Am Diet Assoc. 2006;106:925-45. [pmid: 16812927].
34 Spear BA, Barlow SE, Ervin C, et al. Recommendations for treatment of child and adolescent overweight and obesity. Pediatrics. 2007;120:14. S254–S288.
35 U.S. Food and Drug Administration. Drugs@FDA. U.S. Food and Drug Administration. 2008. Accessed February 25, 2008. http://www.accessdata.fda.gov/scripts/cder/drugsatfda/index.cfm?fuseaction=Search.Search_Drug_Name
36 U.S. Food and Drug Administration. Xenical approval letter. U.S. Food and Drug Administration. 2008. Accessed February 25, 2008. http://www.fda.gov/cder/foi/appletter/2003/20766se5-018ltr.pdf
37 U.S. Food and Drug Administration. Orlistat OTC (marketed as alli) Information. U.S. Food and Drug Administration. 2008. Accessed February 25, 2008. http://www.fda.gov/cder/drug/infopage/orlistat_otc/index.htm
38 Bray GA. Medical therapy for obesity—current status and future hopes. Med Clin North Am. 2007;91(6):1225-53. [pmid: 17964918].
39 Shekelle PG, Morton SC, Maglione M, et al., Pharmacological and Surgical Treatment of Obesity. Summary, Evidence Report/Technology Assessment: Number 103. AHRQ Publication Number 04-E028-1. Rockville, MD, Agency for Healthcare Research and Quality. 2004.
40 Gastrointestinal surgery for severe obesity. Proceedings of a National Institutes of Health Consensus Development Conference. March 25–27, 1991, Bethesda, MD. Am J Clin Nutr. 1992;55:487S–619S.
41 Inge TH, Xanthakos SA, Zeller MH. Bariatric surgery for pediatric extreme obesity: Now or later?. Int J Obes. 2007;31:1-14.
42 Sjostrom L, Narbro K, Sjostrom CD, et al. Effects of bariatric surgery on mortality in Swedish obese subjects. N Engl J Med. 2007;357:741-52. [pmid: 17715408].
43 U.S. Food and Drug Administration. CDRH Internet Home Page. Food and Drug Administration. 2008. Accessed February 2, 2008. http://www.fda.gov/cdrh/pmapage.html
44 Nguyen NT, Root J, Zainabadi K, et al. Accelerated growth of bariatric surgery with the introduction of minimally invasive surgery. Arch Surg. 2005;140:1198-1202. [pmid: 16365242].
45 Inge TH, Krebs NF, Garcia VF, et al. Bariatric surgery for severely overweight adolescents: Concerns and recommendations. Am J Clin Nutr. 2004;114:217-23.
46 Clinical Guidelines on the Identification, Evaluation, and Treatment of Overweight and Obesity in Adults—The Evidence Report. National Institutes of Health. Obes Res. 1998;6 (Suppl 2):51S–209S.
47 Flynn MA, McNeil DA, Maloff B, et al. Reducing obesity and related chronic disease risk in children and youth: A synthesis of evidence with ‘best practice’ recommendations. Obes Rev. 2006;7:7-66. [pmid: 16371076].
48 Collins CE, Warren J, Neve M, et al. Measuring effectiveness of dietetic interventions in child obesity: A systematic review of randomized trials. Arch Pediatr Adolesc Med. 2006;160:906-22. [pmid: 16953014].
49 Summerbell CD, Waters E, Edmunds LD, et al., Interventions for preventing obesity in children. Cochrane Database of Systematic Reviews. 2005(3):CD001871.
50 Connelly JB, Duaso MJ, Butler G. A systematic review of controlled trials of interventions to prevent childhood obesity and overweight: A realistic synthesis of the evidence. Public Health. 2007;121(7):510-7. [pmid: 17467752].
51 Summerbell CD, Ashton V, Campbell KJ, et al., Interventions for treating obesity in children. Cochrane Database of Systematic Reviews. 2003(3):CD001872.
52 Kitzmann KM, Beech BM. Family-based interventions for pediatric obesity: Methodological and conceptual challenges from family psychology. Journal of Family Psychology. 2006;20(2):175-89. [pmid: 16756393].
53 Gutin B, Barbeau P, Owens S, et al. Effects of exercise intensity on cardiovascular fitness, total body composition, and visceral adiposity of obese adolescents. American Journal of Clinical Nutrition. 2002;75:818-26. [pmid: 11976154].
54 Woo KS, Chook P, Yu CW, et al. Effects of diet and exercise on obesity-related vascular dysfunction in children. Circulation. 2004;109:1981-86. [pmid: 15066949].
55 Epstein LH, Wing RR, Penner BC, et al. Effect of diet and controlled exercise on weight loss in obese children. J Pediatr. 1985;107:358-61. [pmid: 4032130].
56 Israel AC, Guile CA, Baker JE, et al. An evaluation of enhanced self-regulation training in the treatment of childhood obesity. Journal of Pediatric Psychology. 1994;19:737-49. [pmid: 7830214].
57 Israel AC, Stolmaker L, Andrian CA. The effects of training parents in general child management skills on a behavioral weight loss program for children. Behavior Therapy. Mar. 1985;16(2):169-180.
58 Wadden TA, Stunkard AJ, Rich L, et al. Obesity in black adolescent girls: A controlled clinical trial of treatment by diet, behavior modification, and parental support 3928. Am J Clin Nutr. 1990;85:345-52.
59 Golan M, Kaufman V, Shahar DR. Childhood obesity treatment: Targeting parents exclusively v. parents and children. Br J Nutr. 2006;95:1008-15. [pmid: 16611394].
60 Golan M, Weizman A, Apter A, et al. Parents as the exclusive agents of change in the treatment of childhood obesity. Am J Clin Nutr. 1998;67:1130-35. [pmid: 9625084].
61 Epstein LH. Effects of family-based behavioral treatment on obese 5-to-8-year-old children. Behavior Therapy. Mar. 1985;16(2):205-212.
62 White MA. Mediators of weight loss in an internet-based intervention for African-American adolescent girls. Obes Res. July. 2004;12(7):1050-1059. [pmid: 15292468].
63 Williamson DA, Walden HM, White MA, et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity. 2006;14(7):1231-43. [pmid: 16899804].
64 Williamson DA, Martin PD, White MA, et al. Efficacy of an internet-based behavioral weight loss program for overweight adolescent African-American girls. Eating & Weight Disorders. 2005;10(3):193-203. [pmid: 16277142].
65 Center for Disease Control and Prevention. BMI Calculator for Child and Teen: English Version. Center for Disease Control and Prevention. 2008. Accessed January 24, 2008. http://apps.nccd.cdc.gov/dnpabmi/Calculator.aspx
66 Center for Disease Control and Prevention. Adult BMI Calculator. Center for Disease Control and Prevention. 2008. Accessed January 24, 2008. http://www.cdc.gov/nccdphp/dnpa/bmi/adult_BMI/english_bmi_calculator/bmi_calculator.htm
67 Cole TJ. The LMS method for constructing normalized growth standards. Eur J Clin Nutr. 1990;44:45-60. [pmid: 2354692].
68 Center for Disease Control and Prevention. A SAS Program for CDC Growth Charts. Center for Disease Control and Prevention. 2008. Accessed May 29, 2008. http://www.cdc.gov/nccdphp/dnpa/growthcharts/resources/sas.htm
69 Carrel AL, Clark RR, Peterson SE, et al. Improvement of fitness, body composition, and insulin sensitivity in overweight children in a school-based exercise program: Arandomized, controlled study. Archives of Pediatrics & Adolescent Medicine. 2005;159:963-68. [pmid: 16203942].
70 Graf C, Koch B, Bjarnason-Wehrens B, et al. Who benefits from intervention in, as opposed to screening of, overweight and obese children?. Cardiology in the Young. 2006;16(5):474-80. [pmid: 16984699].
71 Johnston CA, Tyler C, McFarlin B, et al. Weight Loss in Overweight Mexican American Children: A Randomized Controlled Trial. Am J Clin Nutr. 2007;120:e1450-57.
72 Kalavainen MP, Korppi MO, Nuutinen OM. Clinical efficacy of group-based treatment for childhood obesity compared with routinely given individual counseling. Int J Obes. 2007;31:1500-08.
73 Reinehr T, de Sousa G, Toschke AM, et al. Long-term follow-up of cardiovascular disease risk factors in children after an obesity intervention. American Journal of Clinical Nutrition. 2006;84(3):490-6. [pmid: 16960161].
74 Savoye M, Shaw M, Dziura J, et al. Effects of a weight management program on body composition and metabolic parameters in overweight children: a randomized controlled trial. JAMA. 2007;297(24):2697-704. [pmid: 17595270].
75 Johnston CA, Tyler C, Fullerton G, et al. Results of an intensive school-based weight loss program with overweight Mexican American children. Int J Pediatr Obes. 2007;2:144-52. [pmid: 17999280].
76 Celio AA. Early intervention of eating- and weight-related problems via the internet in overweight adolescents: A randomized controlled trial. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2005;66(4-B):2299.
77 Saelens BE, Sallis JF, Wilfley DE, et al. Behavioral weight control for overweight adolescents initiated in primary care. Obesity Research. 2002;10:22-32. [pmid: 11786598].
78 McCallum Z, Wake M, Gerner B, et al. Outcome data from the LEAP (Live, Eat and Play) trial: A randomized controlled trial of a primary care intervention for childhood overweight/mild obesity. Int J Obes. 2007;31:630-36.
79 Nemet D, Barkan S, Epstein Y, et al. A Short- and long-term beneficial effects of a combined dietary-behavioral-physical activity intervention for the treatment of childhood obesity. Pediatrics. 2005;115(4):e443-49. [pmid: 15687454].
80 Rooney BL, Gritt LR, Havens SJ, et al. Growing healthy families: family use of pedometers to increase physical activity and slow the rate of obesity. WMJ. 2005;104(5):54-60. [pmid: 16138517].
81 Flodmark CE, Ohlsson T, Ryden O, et al. Prevention of progression to severe obesity in a group of obese schoolchildren treated with family therapy. Am J Clin Nutr. 1993;91:880-84.
82 Mellin LM, Slinkard LA, Irwin CE Jr. Adolescent obesity intervention: validation of the SHAPEDOWN program 3987. Journal of the American Dietetic Association. 1987;87:333-38. [pmid: 3819254].
83 Golley RK, Magarey AM, Baur LA, et al. Twelve-month effectiveness of a parent-led, family-focused weight-management program for prepubertal children: A randomized, controlled trial. Am J Clin Nutr. 2007;119:517-25.
84 McCallum Z, Wake M, Gerner B, et al. Can Australian general practitioners tackle childhood overweight/obesity? Methods and processes from the LEAP (Live, Eat and Play) randomized controlled trial. Journal of Paediatrics Child Health. Oct. 2005;41(910):488-94.
85 Braet C, Tanghe A, Bode PD, et al. Inpatient treatment of obese children: A multicomponent programme without stringent calorie restriction. Eur J Pediatr. 2003;162:391-96. [pmid: 12756560].
86 Graf C, Rost SV, Koch B, et al. Data from the StEP TWO programme showing the effect on blood pressure and different parameters for obesity in overweight and obese primary school children. Cardiol Young. 2005;15:291-98. [pmid: 15865832].
87 Gillis D, Brauner M, Granot E. A community-based behavior modification intervention for childhood obesity. Journal of Pediatric Endocrinology. Feb. 2007;20(2):197-203.
88 Senediak C, Spence SH. Rapid versus gradual scheduling of therapeutic contact in a family based behavioural weight control programme for children. Behavioural Psychotherapy. Oct. 1985;13(4):265-287.
89 Doyle AC, Goldschmidt A, Huang C, et al., Reduction of Overweight and Eating Disorder Symptoms via the Internet in Adolescents: A Randomized Controlled Trial. J Adolesc Health.In Press, 2008.
90 Bryant MJ, Lucove JC, Evenson KR, et al. Measurement of television viewing in children and adolescents: a systematic review. Obesity Reviews. 2007;8(3):197-209. [pmid: 17444962].
91 Wilfley DE, Stein RI, Saelens BE, et al. Efficacy of maintenance treatment approaches for childhood overweight: A randomized controlled trial. JAMA. 2007;298:1661-73. [pmid: 17925518].
92 Deforche B, De Bourdeaudhuij I, Tanghe A, et al. Post-treatment phone contact: A weight maintenance strategy in obese youngsters. Int J Obes. 2005;29:543-46.
93 Davis CL, Tkacz J, Gregoski M, et al. Aerobic exercise and snoring in overweight children: a randomized controlled trial. Obesity. 2006;14(11):1985-91. [pmid: 17135615]. [pmcid: 1976410].
94 Sung RY, Yu CW, Chang SK, et al. Effects of dietary intervention and strength training on blood lipid level in obese children. Arch Dis Child. 2002;86:407-10. [pmid: 12023168]. [pmcid: 1763008].
95 Kang HS, Gutin B, Barbeau P, et al. Physical training improves insulin resistance syndrome markers in obese adolescents. Medicine & Science in Sports & Exercise. 2002;34:1920-27. [pmid: 12471297].
96 Golan M, Crow S. Targeting parents exclusively in the treatment of childhood obesity: Long-term results. Obes Res. 2004;12:357-61. [pmid: 14981230].
97 Berkowitz RI, Wadden TA, Tershakovec AM, et al. Behavior therapy and sibutramine for the treatment of adolescent obesity: A randomized controlled trial. JAMA. 2003;289:1805-12. [pmid: 12684359].
98 Berkowitz RI, Fujioka K, Daniels SR, et al. Effects of sibutramine treatment in obese adolescents: A randomized trial. Ann Intern Med. 2006;145:81-90. [pmid: 16847290].
99 Chanoine JP, Hampl S, Jensen C, et al. Effect of orlistat on weight and body composition in obese adolescents: A randomized controlled trial. JAMA. 2005;293:2873-83. [pmid: 15956632].
100 Garcia-Morales LM, Berber A, Ias-Lara CC, et al. Use of sibutramine in obese Mexican adolescents: A 6-month, randomized, double-blind, placebo-controlled, parallel-group trial. Clin Ther. 2006;28:770-82. [pmid: 16861099].
101 Godoy-Matos A, Carraro L, Vieira A, et al. Treatment of obese adolescents with sibutramine: a randomized, double-blind controlled study. Journal of Clinical Endocrinology & Metabolism. 2005;90:1460-65. [pmid: 15613431].
102 Maahs D, de Serna DG, Kolotkin RL, et al. Randomized double-blind placebo-controlled trial of orlistat for weight loss in adolescents. Endocrine Practice. Feb. 2006;12(1):18-28. [pmid: 16524859].
103 Van Mil EG, Westerterp KR, Kester AD, et al. The effect of sibutramine on energy expenditure and body composition in obese adolescents. Journal of Clinical Endocrinology & Metabolism. 2007;92(4):1409-14. [pmid: 17264187].
104 Freemark M, Bursey D. The effects of metformin on body mass index and glucose tolerance in obese adolescents with fasting hyperinsulinemia and a family history of type 2 diabetes. Am J Clin Nutr. 2001;107:E55.
105 Srinivasan S, Ambler GR, Baur LA, et al. Randomized controlled trial of metformin for obesity and insulin resistance in children and adolescents: Improvement in body composition and fasting insulin. J Clin Endocrinol Metab. 2006;91:2074-80. [pmid: 16595599].
106 Budd GM, Hayman LL, Crump E, et al. Weight loss in obese African American and Caucasian adolescents: Secondary analysis of a randomized clinical trial of behavioral therapy plus sibutramine. J Cardiovasc Nurs. 2007;22:288-96. [pmid: 17589281].
107 Daniels SR, Long B, Crow S, et al. Cardiovascular effects of sibutramine in the treatment of obese adolescents: Results of a randomized, double-blind placebo-controlled study. Am J Clin Nutr. 2007;120:e147-57.
108 Sugerman HJ, Sugerman EL, DeMaria EJ, et al. Bariatric surgery for severely obese adolescents. J Gastrointest Surg. 2003;7:102-7. [pmid: 12559191].
109 Tsai WS, Inge TH, Burd RS. Bariatric surgery in adolescents: Recent national trends in use and in-hospital outcome. Archives of Pediatrics & Adolescent Medicine. 2007;161:217-21. [pmid: 17339501].
110 Collins J, Mattar S, Qureshi F, et al. Initial outcomes of laparoscopic Roux-en-Y gastric bypass in morbidly obese adolescents. Surgery for Obesity & Related Diseases. Apr. 2007;3(2):147-52. [pmid: 17324636].
111 Nadler EP, Youn HA, Ginsburg HB, et al. Short-term results in 53 US obese pediatric patients treated with laparoscopic adjustable gastric banding. Journal of Pediatric Surgery. 2007;42(1):137-41. [pmid: 17208554].
112 Lawson ML, Kirk S, Mitchell T, et al. One-year outcomes of Roux-en-Y gastric bypass for morbidly obese adolescents: A multicenter study from the Pediatric Bariatric Study Group. J Pediatr Surg. 2006;41:137-43. [pmid: 16410123].
113 Barnett SJ, Stanley C, Hanlon M, et al. Long-term follow-up and the role of surgery in adolescents with morbid obesity. Surgery for Obesity & Related Diseases. Aug. 2005;1(4):394-8. [pmid: 16925256].
114 Angrisani L, Favretti F, Furbetta F, et al. Obese teenagers treated by Lap-Band System: The Italian experience. Surgery. 2005;138:877-81. [pmid: 16291388].
115 Dolan K, Creighton L, Hopkins G, et al. Laparoscopic gastric banding in morbidly obese adolescents. Obes Surg. 2003;13:101-4. [pmid: 12630622].
116 Dolan K, Fielding G. A comparison of laparoscopic adjustable gastric banding in adolescents and adults. Surg Endosc. 2004;18:45-47. [pmid: 14625730].
117 Widhalm K, Dietrich S, Prager G. Adjustable gastric banding surgery in morbidly obese adolescents: Experiences with eight patients. Int J Obes Relat Metab Disord. 2004;28:S42-45. [pmid: 15543218].
118 Capella JF, Capella RF. Bariatric surgery in adolescence. Is this the best age to operate?. Obes Surg. 2003;13:826-32. [pmid: 14738664].
119 Mason EE, Scott DH, Doherty C, et al. Vertical banded gastroplasty in the severely obese under age twenty-one. Obes Surg. 1995;5:23-33. [pmid: 10733790].
120 Soper RT, Mason EE, Printen KJ, et al. Gastric bypass for morbid obesity in children and adolescents. J Pediatr Surg. 1975;10:51-58. [pmid: 1117394].
121 Anderson AE, Soper RT, Scott DH. Gastric bypass for morbid obesity in children and adolescents. J Pediatr Surg. 1980;15:876-81. [pmid: 7463289].
122 Strauss RS, Bradley LJ, Brolin RE. Gastric bypass surgery in adolescents with morbid obesity. J Pediatr. 2001;138:499-504. [pmid: 11295712].
123 Stanford A, Glascock JM, Eid GM, et al. Laparoscopic Roux-en-Y gastric bypass in morbidly obese adolescents. J Pediatr Surg. 2003;38:430-33. [pmid: 12632362].
124 Breaux CW. Obesity surgery in children. Obes Surg. 1995;5:279-84. [pmid: 10733812].
125 Rand CS, Macgregor AM. Adolescents having obesity surgery: A 6-year follow-up. South Med J. 1994;87:1208-13. [pmid: 7973919].
126 Abu-Abeid S, Gavert N, Klausner JM, et al. Bariatric surgery in adolescence. J Pediatr Surg. 2003;38:1379-82. [pmid: 14523824].
127 Yitzhak A, Mizrahi S, Avinoach E. Laparoscopic gastric banding in adolescents. Obes Surg. 2006;16:1318-22. [pmid: 17059740].
128 Papadia FS, Adami GF, Marinari GM, et al. Bariatric surgery in adolescents: A long-term follow-up study. Surg Obes Relat Dis. 2007;3:465-68. [pmid: 17400517].
129 Silberhumer GR, Miller K, Kriwanek S, et al. Laparoscopic adjustable gastric banding in adolescents: The Austrian experience. Obes Surg. 2006;16:1062-67. [pmid: 16901361].
130 Fielding GA, Duncombe JE. Laparoscopic adjustable gastric banding in severely obese adolescents. Surg Obes Relat Dis. 2005;1:399-405. [pmid: 16925257].
131 Lowry KW, Sallinen BJ, Janicke DM. The effects of weight management programs on self-esteem in pediatric overweight populations. Journal of Pediatric Psychology. 2007 32;10, 1179–95.
132 Epstein LH, Valoski A, McCurley J. Effect of weight loss by obese children on long-term growth. Am J Dis Child. 1993;147:1076-80. [pmid: 8213679].
133 DuBose KD, Eisenmann JC, Donnelly JE. Aerobic fitness attenuates the metabolic syndrome score in normal-weight, at-risk-for-overweight, and overweight children. Am J Clin Nutr. 2007;120:e1262-68.
134 Valdimarsson O, Linden C, Johnell O, et al. Daily physical education in the school curriculum in prepubertal girls during 1 year is followed by an increase in bone mineral accrual and bone width—data from the prospective controlled Malmö pediatric osteoporosis prevention study. Calcif Tissue Int. 2006;78:65-71. [pmid: 16467972].
135 Dowda M, Ainsworth BE, Addy CL, et al. Environmental influences, physical activity, and weight status in 8- to 16-year-olds. Arch Pediatr Adolesc Med. 2001;155:711-17. [pmid: 11386963].
136 Stettler N, Signer TM, Suter PM. Electronic games and environmental factors associated with childhood obesity in Switzerland. Obes Res. 2004;12:896-903. [pmid: 15229327].
137 Crespo CJ, Smit E, Troiano RP, et al. Television watching, energy intake, and obesity in US children: Results from the third National Health and Nutrition Examination Survey, 1988-1994. Arch Pediatr Adolesc Med. 2001;155:360-65. [pmid: 11231802].
138 Robinson TN. Reducing children's television viewing to prevent obesity: A randomized controlled trial. JAMA. 1999;282:1561-67. [pmid: 10546696].
139 Epstein LH, Valoski AM, Vara LS, et al. Effects of decreasing sedentary behavior and increasing activity on weight change in obese children 3814. Health Psychology. 1995;14:109-15. [pmid: 7789345].
140 Epstein LH, Paluch RA, Gordy CC, et al. Decreasing sedentary behaviors in treating pediatric obesity. Arch Pediatr Adolesc Med. 2000;154:220-26. [pmid: 10710017].
141 Epstein LH, Paluch RA, Raynor HA. Sex differences in obese children and siblings in family-based obesity treatment. Obesity Research. 2001;9:746-53. [pmid: 11743058].
142 Daviss WB, Scott J. A chart review of cyproheptadine for stimulant-induced weight loss. Journal of Child & Adolescent Psychopharmacology. 2004;14(1):65-73. [pmid: 15142393].
143 Apovian CM, Baker C, Ludwig DS, et al. Best practice guidelines in pediatric/adolescent weight loss surgery. Obes Res. 2005;13:274-82. [pmid: 15800284].
144 Epstein LH, Valoski A, Wing RR, et al. Ten-year outcomes of behavioral family-based treatment for childhood obesity. Health Psychol. 1994;13:373-83. [pmid: 7805631].
145 Caballero B. The global epidemic of obesity: An overview. Epidemiol Rev. 2007;29:1-5. [pmid: 17569676].
146 Keith SW, Redden DT, Katzmarzyk PT, et al. Putative contributors to the secular increase in obesity: Exploring the roads less traveled. Int J Obes. 2006;30:1585-94.
147 Woodard E. Media in the Home 2000: The Fifth Annual Survey of Parents and Children. 2000. The Anneberg Public Policy Center.
148 Center for Disease Control and Prevention. KidsWalk to School. Center for Disease Control and Prevention. 2008. Accessed January 31, 2008. http://www.cdc.gov/nccdphp/dnpa/kidswalk/then_and_now.htm
149 Participation in high school physical education—United States, 1991-2003. MMWR Morb Mortal Wkly Rep. 2004;53:844–47.
150 Berkey CS, Rockett HR, Gillman MW, et al. One-year changes in activity and in inactivity among 10- to 15-year-old boys and girls: Relationship to change in body mass index. Am J Clin Nutr. 2003;111:836-43.
151 Striegel-Moore RH, Thompson D, Affenito SG, et al. Correlates of beverage intake in adolescent girls: The National Heart, Lung, and Blood Institute Growth and Health Study. J Pediatr. 2006;148:183-87. [pmid: 16492426].
152 Dietz WH. Sugar-sweetened beverages, milk intake, and obesity in children and adolescents. J Pediatr. 2006;148:152-54. [pmid: 16492420].
153 Briefel RR, Johnson CL. Secular trends in dietary intake in the United States. Annu Rev Nutr. 2004;24:401-31. [pmid: 15189126].
154 Ludwig DS, Peterson KE, Gortmaker SL. Relation between consumption of sugar-sweetened drinks and childhood obesity: A prospective, observational analysis. Lancet. 2001;357:505-8. [pmid: 11229668].
155 Center for Disease Control and Prevention. Guide to Community Preventive Services. Center for Disease Control and Prevention. 2008. Accessed January 24, 2008. http://www.thecommunityguide.org
156 Center for Disease Control and Prevention. Healthy Youth! Center for Disease Control and Prevention. 2008. Accessed January 24, 2008. www.cdc.gov/HealthyYouth/overweight/index.htm
157 Hillier A. Childhood overweight and the built environment: Making technology part of the solution rather than part of the problem. The ANNALS of the American Academy of Political and Social Science. 2008;615:56-82.
158 Dietz W, Lee J, Wechsler H, et al. Health plans' role in preventing overweight in children and adolescents. Health Affairs. Apr. 2007;26(2):430-40. [pmid: 17339670].
159 Davis MM, Gance-Cleveland B, Hassink S, et al. Recommendations for prevention of childhood obesity. Pediatrics. 2007;120(14):S229-53. [pmid: 18055653].
160 Robert Wood Johnson Foundation. Program Areas Childhood Obesity. Robert Wood Johnson Foundation. 2008.
161 U.S. National Institutes of Health. ClinicalTrials.gov. U.S. National Institutes of Health. 2008.