# Acknowledgments

We would like to acknowledge the guidance and expertise contributed to this project by the Technical Expert Panel members who are listed in Appendix E. We also thank Stephanie Chang (AHRQ) for her guidance and input throughout the review process, as well as the administrative staff of the Oregon Evidence-based Practice Center, Taryn Cardenas and Debra Burch, for assistance in preparation of the report, and Daphne Plaut for search assistance and document acquisition.