# Results

## Behavioral Interventions

### Trial Characteristics

We identified 18 fair- or good-quality trials, in 21 publications,^69,^ ^70,^ ^72^–^75,^ ^75^–^89^ that evaluated a total of 1,794 overweight or obese children and adolescents. (Tables 3 and 4) These trials compared weight-related outcomes of behavioral weight management interventions to minimal or no treatment control conditions, with outcomes reported at least 6 months after the start of the intervention. Participants in eight ^70,^ ^72,^ ^78^–^81,^ ^83,^ ^88^ of the 18 trials were aged 5 to 12 years (n=900). Four trials^69,^ ^77,^ ^82,^ ^89^ enrolled 12 to 18 year olds (n=246). The remaining six trials^71,^ ^73^–^75,^ ^85,^ ^87^ enrolled both children and adolescents (n=648). Trial participants were mostly female, with the proportion of males generally one third to one half. Before treatment, the mean BMI indicated that most participants in these trials far exceeded the 95^th^ percentile for BMI, and in some cases met adult criteria for Class I obesity.

Table 3 Short-term outcomes of behavioral interventions

Study reference setting | N randomized Age Baseline BMI | Intervention hours (I-C)/intensity Intervention Components | Short-term BMI change: Mean change (SD of change)
Graf et al 2006^70,86^ School | N: 276 Age 6–11 BMI: I (participants): 22.8 ± 3.6 I (non-participants): 21.1 ± 2.4 C: 21.7 ± 2.7 | 175.5 hrs/High I: PA, BehMod, Fam C: Usual school curriculum | [underlined: 9-mo (post-tx)] I (participants): +0.3 ± 1.3 I (non-participants): +0.5 ± 1.3 C: +0.7 ± 1.2
Carrel et al 2005^69^ School | N: 53 Age 12–13 BMI: I: 32 ± 6 C: 30 ± 4 | 67.5 hrs/Medium I: PA C: Typical PE class | [underlined: 9-mo (post-tx)] I: -0.55 ± 1.1^‡^ C: +0.51± 1.7^‡^
Kalavainen et al 2007^72^ School | N: 70 Age 6–9 BMI: I: 23.4 ± 2.6 C: 22.9 ± 2.5 | 45 hrs/Medium I: PA, BehMod, Fam, C: Handouts, 2 counseling meetings | [underlined: 6-mo (post-tx)**] I: -0.8 ± 1.0 C: 0.0 ± 1.1
Johnston et al 2007a^75^ School | N: 71 Age 10–14 BMI: I: 27.7 ± 5.0 C: 25.6 ± 3.4 | 41.5 hrs/Medium I: PA, BehMod, C: Self-help materials | [underlined: 6-mo (post-tx)**] I: -0.16 ± 1.05 C: +0.64 ± 0.90
Johnston et al 2007b^71^ School | N: 60 Age 10–14 BMI: I: 25.4 ± 4.7 C: 26.7 ± 5.5 | 41.5 hrs/Medium I: PA, BehMod C: Self-help materials | [underlined: 6-mo (post-tx)**] I: -0.99 ± 3.79 C: +1.08 ± 1.00
Savoye et al 2007^74^ Health Care | N: 174 Age 8–16 BMI: I: 35.8 ± 7.6 C: 36.2 ± 6.2 | 97.5 hrs/High I: PA, BehMod, Fam, MHTx C: Brief semi-annual counseling | [underlined: 12-mo (post-tx)**] I: -1.7 (3.1) C: +1.6 (3.1)
Reinehr et al 2006^73^ Health Care | N: 240 Age 6–14 BMI: I: 27.0 (26.4, 27.6) C: 26.1 (25.2, 27.8) | 76 hrs/High I: PA, BehMod, Fam, MHTx C: No treatment due to distance from clinic | [underlined: 12-mo (post-tx)**] I: +0.1 (SD NR) C: +2.0 (SD NR)
Golley 2007^83^ Health Care | N=111 Age 6–9 BMI: 24.3 ± 2.6 (overall) | 10.3 hrs (I1), 22 hrs (I2)/Low I1: Fam, MHTx I2: PA, BehMod, Fam, MHTx C: Wait List | [underlined: 12-mo (7-mos post-tx):] NR† BMI SDS: I1: 2.56 ± 0.79 I2: 2.43 ± 0.68 C: 2.60 ± 0.57
Gillis 2007^87^ Health Care | N: 27 Age 7–16 BMI: I: 1.98 ± 0.21 C: 2.16 ± 0.34 | 8 hrs/Very low I: Case manager C: 1 counseling session | [underlined: 6-mo (post-tx)] NR† BMI SDS: I: -0.045 ± 0.19 C: +0.075 ± 0.08
Nemet et al 2005^79^ Child Health and Sports Center | N=54 Average age 11.1 BMI: I: 28.5 ± 4.1 C: 27.8 ± 5.0 | 35.75 hrs/Medium I: PA, BehMod, Fam C (n=24): Nutritional counseling | [underlined: 12-mo (9-mo post-tx)*] I: -2.4 (SD NR) C: +0.8 (SD NR)
McCallum et al, 2007^78,84^ Primary Care | N=163 Age 5–9 BMI: I: 20.5 ± 2.2 C: 20.0 ± 1.8 | 4 hrs/Very low I: BehMod, Fam C: Usual primary care treatment | [underlined: 9-mo (6-mo post-tx):] I: +0.5 (SD NR) C: +0.8 (SD NR)
Saelens et al 2002^77^ Primary Care | N=44 Age 12–16 BMI: I: 31.0 ± 3.5 C: 30.7 ± 3.1 | 3.8 hrs/Very low I: BehMod C: Usual primary care treatment | [underlined: 7-mo (3-mo post-tx)*:] I: +0.1 (NR) C: +1.4 (NR)
Doyle et al, unpub; Celio et al 2006^76^ E-mail, Internet | N=83 Age 12–18 BMI: I: 34.6 ± 7.8 C: 33.9 ± 6.9 | 16 hrs/Low I: BehMod C: Information only | [underlined: 8-mo (4-mo post-tx):] I: -0.2 (SD NR) C: +0.4 (SD NR)
Braet et al 2003^85^ Residential | N: 76 Age 10–17 BMI: I: 33 (SD NR), C: 33 (SD NR) | 3,520 hrs/Very high I: PA, BehMod, MHTx C: Wait List | [underlined: 10-mo (post-tx)**]: NR† %OW: I: -51 (SD NR) C: +6 (SD NR)
Rooney 2005^80^ Community | N=98 families Age 5–12 BMI: NR | 3 hrs (I1), 21 hrs (I2)/Very low; Low I1: Fam I2: Fam C: Not described | [underlined: 9-mo (6 mo post-tx):] NR‡ I1&I2: -0.87 ± 1.27 C: -0.43 ± 1.07
Senediak et al 1985^88^ Setting NR | N=35 Age 6–12 BMI: I: 20.5 ± 2.2 C: 20.0 ± 1.8 | 12 hrs (I1, I2, C)/Low I1: BehMod, Fam I2: BehMod, Fam C: Social support, relaxation, mood monitoring | [underlined: 6-mo (3–5 mo post-tx)*:] NR† (%OW I1: -13.04 (SD NR) I2: -19.22 (SD NR) C: -5.86 (SD NR))

Note: Interventions ordered first by setting and second by intensity.

Abbreviations: I- Intervention group; C- Control group; NR-Not Reported; PA-organized physical activity sessions; BehMod-behavioral modification principles; Fam-parent participant; MHTx-mental health treatment beyond behavioral modification; post-tx-post treatment; SD-standard deviation

* p<0.05;

** p<0.01, bold if p<0.05

† BMI not reported, so other outcome listed

‡ Unpublished data supplied by author

Table 4 Maintenance outcomes of behavioral interventions

Study reference | N randomized Age range Baseline BMI Setting | Intervention hours (in excess of control group hours of contact) /Intensity; Intervention components | Maintenance BMI Change: Mean change (SD of change)
Kalavainen et al 2007^72^ School | N=70 Age 6–9 BMI: I: 23.4 ± 2.6 C: 22.9 ± 2.5 | 45 hrs/Medium I: PA, BehMod, Fam C: Handouts, 2 counseling mtgs | [underlined: 18-mo (12-mos post-tx)*] I: 0.1 ± 1.2 C: 0.8 ± 1.3
Reinehr et al 2006^73^ Health Care | N=240 Age 6–14 BMI: I: 27.0 (26.4, 27.6) C: 26.1 (25.2, 27.8) | 76 hrs/High I: PA, BehMod, Fam, MHTx C: No treatment d/t distance | [underlined: 24-mo (12-mos post-tx)**] I: +1.2 (SD NR) C: +2.9 (SD NR)
Mellin et al 1987^82^ Health Care | Age 12–18 (15.6) N=66 BMI: NR | 24 hrs/Low I: PA, BehMod C: No treatment | [underlined: 15-mo (12-mo post-tx)]†: NR‡ Percent Overweight: I: -9.9 ± 15.0 (p<0.01)** C: -0.1 ± 13.2 (n.s.)**
Flodmark 1993^81^ Health Care | N=93 Age 10–11 BMI: I1: 25.5 ± 0.53* I2: 24.7 ± 0.36* C: 25.1 ± 0.35* | 12 hrs (I1), 24 hrs (I2)/Low I1: Fam I2: Fam, MHTx C: Matched controls, no treatment | [underlined: ~48-mo (30–34 mo post-tx)*:] I1: +1.6 (SD NR) I2: +1.1 (SD NR) C: +2.8 (SD NR)
McCallum et al, 2007^78,84^ Primary Care | N=163 Age 5–9 BMI: I: 20.5 ± 2.2 C: 20.0 ± 1.8 | 4 hrs/Very low I: BehMod, Fam C: Usual primary care treatment | [underlined: 15-mo (12-mo post-tx):] I: +1.2 (NR) C: +1.2 (NR)

Note: Interventions ordered first by setting and second by intensity.

Abbreviations: I- Intervention group; C- Control group; NR- Not Reported; PA- Intervention included organized physical activity sessions; BehMod- Intervention included instruction in behavioral modification principles; Fam- Parent was a primary participant in the intervention; MHTx- Mental Health treatment beyond behavior modification related to diet and exercise was provided; n.s.-not statistically significant; post-tx-post treatment; SD-standard deviation.

* p<0.05 or believed likely to be p<0.05;

** p<0.01; bold if p<0.05 or likely to be p<0.05.

† no direct comparisons reported, but differences between paired t-tests suggests p<0.05.

‡ BMI not reported, so other outcome listed.

Two trials were conducted in primary care settings,^77,^ ^78^ five in specialty health care settings,^73,^ ^74,^ ^79,^ ^83,^ ^87^ five in school settings,^69^–^72,^ ^75^ one in a residential setting,^85^ one in a child health/sports center,^79^ one using the internet,^89^ and three in settings that were not described.^80,^ ^81,^ ^88^ Eight studies were conducted in the United States, three in Australia, three in Germany, two in Israel, and one each in Belgium, Finland, and Sweden. A total of 22 different active treatment arms were evaluated. Duration of treatment ranged from 3 to 12 months, with the exception of one study with a “rapid pace” treatment arm lasting only 4 weeks,^88^ and a longer trial that lasted for 14 to 18 months.^81^ Treatment intensity (estimated in hours of contact) ranged from 3.8 to 3,520 hours, with 16.7 percent (n=3) providing less than 10 hours, 33.3 percent (n=6) providing 10–25 hours, and 33.3 percent (n=6) providing 26–75 hours. The remaining three trials provided considerably more than 75 hours (97.5, 175.5, and 3,520 hours).

Ten of the trials involved the parents as primary participants in the intervention.^70,^ ^72^–^74,^ ^78^–^81,^ ^83,^ ^88^ All but one^74^ of these trials involved children aged 11 years and younger on average. Parental involvement took many forms in these trials, including weight control educational sessions (with or without their overweight child),^70,^ ^72,^ ^74,^ ^78^–^80,^ ^84,^ ^86,^ ^88^ family therapy,^73,^ ^81^ or parenting skills training.^83^ Family involvement in the remaining eight trials ranged from no involvement to including parents in one to three counseling sessions. The trials with less parent involvement primarily targeted older children, although three included those as young as 10 years,^71,^ ^75,^ ^85^ and one included children as young as 7 years.^87^

Participants engaged in organized physical activity sessions as part of the intervention in eleven of the trials.^69^–^75,^ ^79,^ ^82,^ ^83,^ ^85^ Four additional trials^77,^ ^78,^ ^88,^ ^89^ applied behavioral modification principles to help participants increase their physical activity on their own time. Three trials provided only information and encouragement for physical activity, but did not apply behavioral modification principles such as problem-solving and goal-setting to physical activity.^80,^ ^81,^ ^87^

While all 18 trials provided short- or long-term changes in weight after treatment, not all trials provided data on all outcomes (Tables 3 and 4). Sixteen trials reported short-term weight outcomes (within 6–12 months from enrollment) measured immediately or several months after treatment ended.^69^–^75,^ ^77^–^80,^ ^83,^ ^85,^ ^87^–^89^ Five trials addressed maintenance outcomes more than 12 months after treatment ended.^72,^ ^73,^ ^78,^ ^81,^ ^82^ Eight trials reported adverse events,^69,^ ^73,^ ^74,^ ^77,^ ^78,^ ^82,^ ^83,^ ^85,^ ^89^ and 11 reported other beneficial outcomes in addition to weight.^69^–^71,^ ^73^–^75,^ ^79,^ ^81,^ ^83,^ ^87,^ ^88^ (Further trial details included in Appendix C ^†^ Table 1.)

† Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/childweight/chweight.pdf.

Additional trials that did not meet inclusion criteria for weight outcomes, but did for other key questions, are detailed in the sections addressing those key questions.

Study design and quality. We rated eight^71,^ ^72,^ ^74,^ ^75,^ ^77,^ ^78,^ ^83,^ ^89^ of the 18 trials as good-quality. The remaining trials were rated as fair-quality. Most trials (n=14) were randomized controlled trials but three were nonrandomized controlled trials.^73,^ ^81,^ ^85^ It was unclear whether one fair-quality trial involved randomization.^82^ Eleven of the 16 trials using randomization failed to report whether treatment allocation was blinded. Fifteen of the 18 trials did not report whether those conducting followup assessments were blind to the treatment condition. Many of the trials were also quite small, with 12 of 18 trials including 40 or fewer participants per treatment arm. While most trials reported retention of around ninety percent or higher, but it was below 70 percent in three trials.^74,^ ^87,^ ^88^ One trial ^74^ among these used statistical methods to compensate for attrition. Several trials tested for differential attrition statistically (none found differential attrition between treatment and control groups), but most did not. While two smaller trials^77,^ ^90^ appeared to have differential attrition, these differences were not tested statistically. The majority of trials (13/18, 72.2 percent) were published in 2005 or later.

### Short-term (6–12 month) Weight Outcomes with Behavioral Interventions (KQ1)

Sixteen trials^69^–^75,^ ^77^–^80,^ ^83,^ ^85,^ ^87^–^89^ measured short-term weight outcomes (6 to 12 months after entry into treatment). Two^73,^ ^83^ of these trials reported actual BMI measures between groups, but tested only whether BMI trends from baseline to followup were significantly different. Most trials reported weight outcomes as post-intervention BMI or changes in BMI from baseline and compared these changes between intervention and control groups. Among trials that did not report BMI or change in BMI, two trials, reported weight outcomes as changes in BMI standard deviation scores (SDS),^83,^ ^87^ two trials reported changes in percent overweight,^85,^ ^88^ and one trial reported change in BMI percentile.^80^ All studies involved children and/or adolescents whose BMI exceeded the 97^th^ percentile on average.

All trials except one^80^ were consistent with a beneficial effect of treatment on BMI change compared with controls. Not all of these differences, however, were statistically significant. Programs conducted in the outpatient setting or the community generally showed only modest differences in BMI change between treatments and controls. In most cases participants remained at or above the 95^th^ percentile after completing the interventions. The greatest level of weight loss was seen in 76 youth aged 10 to 17 years participating in a very high-intensity (3250 hours), 10-month residential program. Average weight decreased from 75 percent overweight to 24 percent overweight in the intervention group, compared to a 6 percent increase in those on a waiting list.^85^

Most (12 of 15) outpatient or community trials reported weight outcomes as mean post-test BMI or change in BMI (Figure 4). In these programs, short-term BMI changes in intervention groups ranged from dropping 2.4 kg/m^2^ in BMI to increasing BMI by 0.5 kg/m^2^. Control group BMI changes ranged from dropping 0.43 kg/m^2^ to increasing BMI by 2.0 kg/m^2^. Net short-term *improvements in BMI change between intervention and control groups ranged from 0.3 to 3.30 kg/m^2^ and these differences reflected weight loss as well as weight gain prevention among treated participants. Two of the other four trials reporting weight outcomes other than BMI change showed a benefit with treatment. One of these, conducted in a health care setting, showed a significant difference (1.2 BMI SDS) favoring treatment 6 months after a low-intensity (8 hours) intervention in young people aged 7 to 16 years (n=27),^87^ while another, also in a health care setting, showed no treatment benefit (measured in BMI SDS) at one year after either 10 or 21 hours of treatment delivered over 5 months to 6 to 9 years olds (n=111).^83^ In a community setting, both a very-low (3 hours) or low-intensity (21 hours) behavioral intervention delivered over 3 months to 5 to 12 year olds (n=98) resulted in an increased BMI percentile in the intervention group, and a decreased BMI percentile in the control group, with no overall statistical differences.^80^ In one study, conducted in an unknown setting, a low-intensity (12 hours) intervention in 6–12 year olds (n=35) significantly reduced the mean percent overweight (13 to 19 percentage points), compared with a 6 percent reduction in the minimally treated control condition.^88^

Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/childweight/chweight.pdf.

Figure 4. Pooled analysis: Short-term effect size of behavioral interventions (KQ1)

A meta-analysis of the 12 trials reporting sufficient data to analyze group differences in short-term BMI change after behavioral interventions found an average difference in BMI change of 1.22 kg/m^2^ between treatment and control participants that favored treatment (CI: 0.75, 1.69). Statistical testing for heterogeneity (I^2^=84.3 percent), however, indicated large differences in estimates across studies. Statistical heterogeneity was reduced when stratified by setting. (Figure 4).

School setting. Among the five studies of predominantly medium-intensity behavioral interventions in school settings,^69^–^72,^ ^75^ (Figure 4, sub-category 1) average BMI change was 0.81 kg/m^2^ greater in treatment than control participants (CI: 0.45, 1.18). Results were relatively homogeneous across studies (I^2^=47.2 percent) and studies included a range of ages (6 to14 years).

Health care referral or specialty settings. Short-term outcomes from the three trials of medium- to high-intensity interventions in health care referral or specialty treatment settings (Figure 4, sub-category 2) showed the largest difference in mean BMI change between treatment and controls of all community settings (1.9 kg/m^2^ to 3.3 kg/m^2^).^73,^ ^74^ These trials had a pooled estimate of 2.73 kg/m^2^ (CI: 1.72, 3.73) and a statistical result (I^2^ =70.9 percent) indicating these three estimates of specialty treatment do not appear to be comparable. When absolute weight reduction was considered as a percentage of baseline BMI, these treatments resulted in comparable weight differences (7 to 9 percent difference). As discussed above, results of the two lower-intensity interventions in health care settings that were not included in the meta-analysis resulted in mixed findings.^83,^ ^87^

Primary care setting. Short-term changes in weight in two trials ^77,^ ^78^ of very-low-intensity (4 hours) interventions conducted in primary care settings (Figure 4, sub-category 3) were smaller than in specialty settings (0.3 to 1.3 kg/m^2^). The pooled average BMI change indicated statistical heterogeneity (I^2^=62.5 percent), consistent with noncomparable treatment effects. These studies addressed very different ages (5–9 years in one compared with 12–16 years in the other) and, as such, mean BMIs at baseline were very different (20 kg/m^2^ vs. 31 kg/m^2^). Thus, while a modest benefit for low-intensity primary care interventions is adolescents is possible, this type of intervention was not clearly beneficial in the single trial of younger children and their families.

Other settings. A single study in a self-referred community setting using pedometers (with or without additional weight management education) to increase physical activity and affect BMI showed little effect on BMI. After nine months, control participant's BMI dropped by an average of 0.43 kg/m^2^ and intervention participant's BMI decreased by 0.87 kg/m^2^ (Figure 4 sub-category 4).^80^ Similarly, a single study examining an internet-based intervention in adolescents (12–18 years) showed little impact on followup BMI at 8 months (4 months after treatment ended). Participants in the intervention group decreased BMI by 0.15 kg/m^2^, while those in the control group increased by 0.39 kg/m^2^ (p=0.10) (Figure 4 sub-category 5).^89^

Best case example from a healthcare setting. One good-quality trial conducted by Savoye and colleagues^74^ illustrates a realistic best-case scenario, reporting the largest effect size of the outpatient programs included in this review and a comprehensive program in which many families with overweight children could realistically participate, if it were available to them and affordable. This year-long program (Bright Bodies Weight Management) at a pediatric obesity clinic in the United States accepted children ranging from age 8 to 16 years, with an average age of 12.1 years. Sixty-one percent of the 174 participants were girls. The Bright Bodies program involved approximately 98 hours of contact and an extensive educational program providing information on nutrition, physical activity, behavior change strategies, coping skills, and relapse prevention. They provided organized exercise sessions twice per week during the first 6 months, then once every two weeks during the next 6 months. Parents or caregivers attended all educational sessions. Children and adolescents in the intervention group began the program with an average BMI of 35.8 kg/m^2^, which dropped by an average of 1.7 kg/m^2^ by the end of the intervention, compared with an average increase of 1.6 kg/m^2^ in the control group. This trial suffered from somewhat low retention (77.6 percent at 6 months and 66.7 percent at 12 months), but took statistical measures to examine and combat the effects of attrition, including comparing results in completers only with results involving multiple imputation and Last Observation Carried Forward (LOCF) data replacement methods.

To provide a more concrete example of the average impact of the Bright Bodies program, we modeled the impact on a 12-year-old girl who began the program at an assumed height of 5′0", with the average entry BMI of 35.8, and who experienced the average reduction in her BMI by 1.7 kg/m^2^ over the course of the intervention year, while growing 2 inches (an average for this age and sex). This would amount to a change from 183 pounds to 186 pounds one year after she participated in the program, compared with an expected 21 pound weight gain and an increase of 1.6 BMI kg/m^2^ if she had not participated.

### Maintenance of Weight Changes After Behavioral Interventions (KQ2)

Five trials in six publications^72,^ ^73,^ ^78,^ ^81,^ ^82,^ ^84^ reported medium-term outcomes at least 12 months after the intervention began and 1–5 years since beginning treatment. Three of these trials also reported short-term (6 to12 month) weight outcomes.^72,^ ^73,^ ^78^ No trials reported longer-term (more than 5 years) outcomes. Three trials were set in specialty health care treatment settings,^73,^ ^81,^ ^82^ one in primary care,^78^ and one in schools.^72^ All of these trials reported weight outcomes in kg/m^2^, except an older study reporting change in percent overweight (see Table 4).^82^

Three of the five interventions in trials reporting maintenance outcomes tested low-,^81^ medium-,^72^ or high-intensity^73^ interventions delivered over 6 months or longer. The remaining two trials tested interventions lasting 3 months that were very low^78^ or low intensity.^82^ Some of these trials also report 6-to 12-month outcomes that were described under KQ1.

We considered the results of the five trials reporting maintenance outcomes qualitatively, as there was significant statistical heterogeneity when we pooled them (I^2^ =89.5 percent) or stratified to include those in the health care setting (I^2^ =55.6 percent) (Figure 5). Four of the five trials, including one reporting results as change in percent overweight,^82^ found that intervention groups had beneficial changes in BMI compared to controls at least one year after treatment began.^72,^ ^73,^ ^81,^ ^82^ However, BMI in the intervention groups decreased from baseline in only one of five studies (that only included adolescents).^82^ These results suggest that the primary sustained benefit of treatment, particularly in younger children, was preventing the degree of weight gain seen in controls. Two of the three trials reporting both short-term and maintenance outcomes 12 months later confirmed that BMI benefits seen at 6–12 months were largely maintained.^72,^ ^73^ The third trial with both short-term and maintenance outcomes did not find improved weight outcomes at either 12 or 15 months and was a very low-intensity (4 hours), short-duration (3 month) treatment.^78^ In one trial testing a low-intensity (24 hours), short-duration (3 month) intervention, there was a greater difference in overweight measures between intervention and controls at 15 months than at 3 months.^82^ This result was the only one to suggest that treatment effects could be enhanced beyond the end of active treatment.

Figure 5. Pooled analysis: Maintenance effect size of behavioral interventions (KQ2)

Post-treatment strategies. Two comparative-effectiveness trials also tested post-treatment strategies to enhance weight maintenance after a high-intensity inpatient treatment program and a moderate-intensity outpatient treatment program (see Appendix C Table 2 for detailed information on these supplementary trials).^91,^ ^92^ After 10 months of intensive residential treatment for 20 adolescents, Deforche and colleagues found that 1.7 hours (compared with 0.25 hours) of telephone and mail contact over 6.5 months was beneficial in preventing some weight regain. After completion of a moderate-intensity outpatient treatment program that reduced BMI (measured in standard deviations) in 150 children aged 7 to 12 years, those who received 16 hours of behavioral self-management support or social support over four months maintained BMI improvements, compared with those who received no support. However, between group differences were no longer apparent 8 and 20 months after the end of maintenance treatment.

### Adverse Effects of Behavioral Interventions (KQ3)

Eight^69,^ ^74,^ ^77,^ ^78,^ ^82,^ ^83,^ ^85,^ ^89^ of 18 trials addressing weight outcomes also reported potential harms of behavioral weight management interventions (Table 5). In order to more fully illuminate serious adverse events (i.e., those requiring urgent medical treatment), we eliminated the minimal followup time criterion of 6 months for beneficial outcomes based on the assumption that adverse effects could happen well before a treatment effect is apparent. We also eliminated the requirement that the trial be conducted in a country with a United Nations Human Development Index (HDI) (http://hdrstats.undp.org/indicators/1.html) of >0.90, based on our assumption that cultural conditions are unlikely to affect likelihood of injury. Thus, two supplementary trials^93,^ ^94^ reporting on injury rates in exercise programs with obese children were included. These trials did not meet criteria for inclusion for the previous questions because they only reported weight outcomes of less than 6 months.

Table 5 Potentially harmful effects of behavioral interventions for childhood overweight

Study reference | Patient characteristics | Description of intervention groups | Outcomes of all potential harmful effects examined
Height
Braet et al 2003^85^ | 10–17 (13) N=76 Residential Belgium | I (n=38): 10-month residential weight loss treatment, minimal parental involvement, included organized PA C (n=38): Waiting list | No group differences in change in height at 10 months
Savoye et al 2007^74^ | Age 8–16 (12.1) N=174 Health Care USA | I (n=105): Bright Bodies Weight Management: nutrition education and behavior modification class, substantial parental involvement, included organized PA C (n=69): Brief semi-annual counseling | No group difference in changes in height at 6 months or 12 months
Golley 2007^83^ | Age 6–9 (8.2) N=111 Health Care Australia | I1 (n=37): Parenting skills training with emphasis on dietary and PA issues, no organized PA I2 (n=38): Above + Intensive weight loss education (lifestyle approach), included organized PA C (n=36): Wait-list Control, 3–4 brief phone calls to encourage retention in study | No group difference in changes in height at 12 months
Eating Pathology and Body Image
Carrel et al 2005^69^ | Age 12–13 (12.5) N=53 School USA | I (n=27): PE class emphasizing non-competitive movement activities, small class size; minimal parental involvement, included organized PA C (n=26): PE class, typical competitive, team sports emphasis | Among treatment participants, measures of “drive for thinness” and “external eating” declined, self-reported ratings of physical appearance, athletic competence, and social acceptance improved.
Saelens et al 2002^77^ | Age 12–16 Mean 14.2 ± 1.2 N=44 Primary Care USA | I (n=23): Healthy habits intervention: Primary care-based tailored weight loss intervention, minimal parental involvement, no organized PA C (n=21): Usual primary care treatment | Problematic eating/eating disorder psychopathology did not differ between groups
Doyle et al, unpub; Celio et al 2006^76^ | Age 12–18 (14.5) N=83 Internet USA | I (n=42): Internet-delivered, interactive, moderated cognitive-behavioral program, limited parental involvement, no organized PA C (n=41): Basic, non-interactive information on nutrition and physical activity | Control group showed greater decline in Shape Concern than Intervention group; no other differences in eating disorder pathology
McCallum et al, 2007^78,84^ | Age 5–9 (7.4) N=163 Primary Care Australia | I (n=82): Primary care-based wt loss intervention, including brief solution-focused intervention, parent as agent of change; no organized PA C (n=81): Usual care | No differences on child-reported ratings of body satisfaction or appearance/self-worth
Other
Mellin et al 1987^82^ | Age 12–18 (15.6) N=66 Health Care USA | I (n=37): SHAPEDOWN program, comprehensive weight loss treatment, minimal parental involvement, included organized PA C (n=29): no treatment controls | Depression improved in treatment group, did not change in control group.
Supplementary Trials, Injuries Related to Physical Activity
Sung et al 2002^94^ | Age 8–11 N=82 NR China | I (n=41): 6-week diet program + supervised physical training C(n=41) 6-week diet program, no organized PA | No training-related injuries. (Baseline BMI 25.5)
Davis et al 2006^93^ | Age 7–11 N=100 Health Care USA | I1: 13 weeks low-dose aerobic exercise (20 min/day) I2: 13 weeks High-dose aerobic exercise (42 min/day) C: No exercise control | 1 bone fracture in exercising group (11 and I2 combined) (Baseline BMI 26.5)

Abbreviations: PA-physical activity; PE-physical education; tx-treatment

We found no evidence that behavioral intervention programs may be harmful. Among the eight trials, three ^74,^ ^83,^ ^85^ reported no group differences in change in height measured at 10 to 12 months. Four trials ^69,^ ^77,^ ^78,^ ^89^ reported either favorable or no effects on several measures of eating disorder pathology or body image/physical self-concept. One trial^82^ reported that depression symptomatology improved in intervention group participants, but did not change in the control group, which represents an added benefit rather than an adverse effect. In addition, Nemet and colleagues^79^ reported that no adverse events were noted, but did not describe what events they examined or how they elicited information on adverse events. In the two trials examining injuries in exercise programs, Sung and colleagues^94^ reported that none of the 41 obese children in their exercise condition were injured, and only one of the 73 obese children in the trial by Davis and colleagues^93^ fractured a bone. No children in the control groups of either of these trials reported any injuries.

### Other Beneficial Outcomes of Behavioral Interventions (KQ4)

Eleven ^69^–^71,^ ^73^–^75,^ ^79,^ ^81,^ ^83,^ ^87,^ ^88^ of the 18 trials reported other beneficial outcomes, including measures of adiposity, cardiovascular risk factors, and physical fitness (Table 6). Intermediate outcomes included improved nutrition and activity level, and self-reported measures of self-concept, mental health, or eating disorder-related behaviors. Results in all areas were mixed, but the outcomes that primarily showed improvement in the intervention group relative to the control groups were measures of adiposity, fasting insulin, and glucose tolerance. Improvements in physical fitness appeared related to whether organized physical activity sessions were provided.

Table 6 Other positive medical outcomes reported in behavioral intervention trials

Study reference | Increase in high-density lipids (HDL) | Decrease in Low-density lipids (LDL)† | Decrease in triglycerides | Decrease in systolic BP | Decrease in diastolic BP | Decrease in fasting glucose | Decrease in fasting insulin | Decrease in HOMA-IR | Adiposity (Measure)
Carrel et al 2005^69^ | — | — | — | — | — | N | IG | — | IG: DEXA; decrease in % of body fat
Flodmark 1993^81^ | — | — | — | — | — | — | — | — | IG: Triceps, subscapular, suprailiac skinfold; decrease in thickness
Gillis 2007^87^ | N | N | N | — | — | — | — | — | —
Golley 2007^83^ | N | — | N | N | N | N | N | — | IG: decrease in Waist circumference
Graf et al 2006^70,86^ | — | — | — | — | — | — | — | — | N: decrease in Waist circumference
Johnston et al 2007a^75^ | N | N | N | N | N | N | N | — | IG: Bioelectric impedance; decrease in body fat percentage
Johnston et al 2007b^71^ | N | IG | N | N | N | N | N | — | N: Bioelectric impedance; decrease in body fat percentage
Nemet et al 2005 ^79^ | — | — | — | — | — | — | — | — | IG: Triceps, subscapular skinfold; decrease in thickness
Reinehr et al 2006^73^ | N | IG | N | IG | N | N | IG | IG | —
Savoye et al 2007^74^ | N | N | N | — | — | N | IG | IG | IG: Bioelectric impedance; decrease in body fat percentage
Senediak et al 1985^88^ | — | — | — | — | — | — | — | — | IG: Subscapular skinfold; decrease in thickness

N - No group differences, IG - Result favors intervention group

† HDL and LDL differences are reported separately; trials do not report on the ratio of HDL to LDL

BP- blood pressure; DEXA - Dual-energy x-ray absorptiometry; HOMA - homeostasis model assessment of insulin resistance

Measures of adiposity. Nine of these eighteen trials ^69^–^71,^ ^74,^ ^75,^ ^79,^ ^81,^ ^83,^ ^88^ reported measures of adiposity. In most cases these trials found that the intervention groups showed greater improvement in these measures than those in the control groups. Six trials^69,^ ^74,^ ^75,^ ^79,^ ^81,^ ^88^ found positive effects in both the primary weight outcome and either skinfold measures or body fat, as measured by bio-electrical impedance. One more trial ^83^ that did not have positive primary weight outcomes did show improvement in adiposity (as measured by DEXA)^69^ and waist circumference. ^70,^ ^83^ The remaining two trials did not see group differences in adiposity as measured by bio-electrical impedance^71^ or waist circumference.^70^

Health outcomes. Other outcomes explored included lipid levels, glucose tolerance, blood pressure, and physical fitness. Results for all of these outcomes were quite mixed. Reported differences were most commonly reductions in LDL cholesterol levels, reduced fasting insulin, and reduced insulin resistance. Three^69,^ ^73,^ ^74^ of the six^69,^ ^71,^ ^73^–^75,^ ^83^ trials reporting on fasting insulin found reductions of fasting insulin in the intervention groups relative to the control group. Two of these trials^73,^ ^74^ also reported significant reductions in insulin resistance, as measured by the homeostasis model assessment of insulin resistance (HOMA). By contrast, none of the six trials ^70,^ ^71,^ ^73^–^75,^ ^83^ reporting lipid levels found group differences in HDL or triglyceride levels, and only two found reductions in LDL levels.^71,^ ^73^

None of the four trials^71,^ ^73,^ ^75,^ ^83^ reporting on blood pressure found group differences on diastolic blood pressure and only one^73^ reported reductions in systolic blood pressure. Similarly, none of the five trials ^71,^ ^73^–^75,^ ^83^ reporting on glucose levels found any group differences.

Four trials ^69,^ ^79,^ ^81,^ ^87^ reported on physical fitness, each using a different measure. Results suggest that organized physical activity increased physical fitness, though one trial ^81^ did achieve improvement without organized exercise sessions (further details in Appendix C ^†^ Table 1). The trial by Carrel and colleagues ^69^ found that the intervention group improved their maximum oxygen consumption more than the control group in a trial comparing a specially designed, limited-enrollment physical education class that emphasized noncompetitive, lifestyle movement activities (e.g., walking, cycling, and snowshoeing) with a typical physical education class. Nemet and colleagues^79^ reported increased endurance in the participants in their intervention group after completing a 14-week, twice-weekly exercise program along with up to six meetings with a dietitian. This study measured endurance by the number of seconds participants were able to continue a treadmill test. One trial^87^ that did not include organized exercise sessions did not see group differences in scores on the Harvard Step Test. On the other hand, Flodmark and colleagues^81^ did not provide organized physical activity, yet children in one of the treatment conditions had greater physical work capacity at one-year followup than those in the control group, controlling for baseline scores. So, the provision of organized physical activity sessions was not necessary to improve children's fitness.

Behavior changes. The interventions in these trials appeared to have a minimal impact on the intermediate outcomes of diet and activity level. While four trials^77^–^79,^ ^87^ explored dietary changes, only one^78^ found group differences. The only dietary differences found in this study were that children in the intervention group reported consuming less whole milk, while consuming more skim milk and water. Five trials^77^–^80,^ ^87^ reported on changes in physical activity levels and/or sedentary behavior. Only one reported positive effects.^79^ This trial provided organized physical activity sessions during the 3-month intervention, and measured the amount of sedentary and physical activity participants reported 1 year later. Participants in the intervention group reported an average of 6 fewer minutes of screen time per day and 9.1 more weighted metabolic-equivalent units of habitual activity. This suggests that long-term changes in physical activity can be sustained even after only 3 months of intervention. The remaining four trials, which showed no group differences, included one trial targeting physical activity,^80^ two low-intensity primary care-based trials,^77,^ ^78^ and a small (n=27), low-intensity trial involving weekly brief contact with a case manager.^87^

Eating disorders. Finally, several trials measured constructs such as impacts on eating disorders or body image that may be a potential harm or benefit of a treatment program. No group differences were found in either of the two trials ^77,^ ^89^ reporting on eating disorder pathology. Instead, Doyle and colleagues^89^ reported reduced levels of shape concern in the intervention participants in their trial. Mellin and colleagues ^82^ found reductions in depression scores among intervention participants and no changes in depression scores in control participants. They did not, however, directly test the groups against each other. Also, Mellin and colleagues did not find group differences in change in self-esteem and both groups showed improvement in repeated measures tests.

### Important Components of Behavioral Interventions (KQ5a)

We approached the question of identifying important components of treatment by first examining the results of the primary group of eighteen KQ1 and KQ2 trials. Treatment approaches generally focused on making healthy lifestyle improvements, emphasizing healthy eating, and increased physical activity. Table 7 provides more detailed information on intervention components used in trials that found significant treatment effects. However, treatment approaches and the components of treatments were quite heterogeneous (Table 3 and 4 and Appendix C ^†^ Table 1). The number of trials was also too small to permit quantitative examination of the variation in treatment components through meta-regression. Therefore, we coded three treatment components possibly related to treatment success: the provision of organized physical activity sessions as part of the intervention, parental involvement within age groups, and the utilization of behavior modification principles. We then sorted the trials by each of these variables and examined the overall patterns of variation in treatment components and their association with statistically significant effects on weight outcomes (see Appendix J ^†^). We supplemented this approach by including comparative effectiveness trials addressing any of these three treatment components that met all criteria for KQ1 and/or KQ2, except that they did not include a minimal-treatment control group.

We discuss our findings from this exercise, but these should be considered primarily as hypothesis-generating. The degree of variability among this small number of treatment programs, including important differences in effects due to setting, age and treatment intensity, greatly limits our ability to examine other treatment components.

Organized physical activity sessions. Programs that provided organized physical activity sessions (rather than encouraging participants to exercise at home) appeared to be more likely to improve BMI. Group differences were seen in eight of 11 programs with organized physical activity sessions. The three trials that did not see beneficial changes in BMI reported improvements in other weight or adiposity measures. We did not have sufficient data to ^†^determine whether programs with organized physical activity or those that improved physical activity or fitness were more likely to have a positive impact on other health outcomes (such as fasting insulin or blood pressure). The physical activity sessions ranged from seven 1-hour sessions at 2- to 4-week intervals, which consisted of fun, noncompetitive physically active games and activities,^83^ to twice-weekly 50-to 60-minute sessions for 6 to 9 months.^70,^ ^74^ Efforts were generally made to present a variety of enjoyable activities, including team sports, noncompetitive games, dancing, swimming, walking, jogging, and obstacle courses. Several trials^72,^ ^79,^ ^83^ employed activities to help develop motor skills and one^69^ reported making efforts to personalize the skill level of the activities to the skill levels of the child. One trial ^74^ used exercise physiologists to facilitate the exercise sessions and help children maintain a target heart rate of 65 to 80 percent of their age-adjusted maximal heart rate.

We identified three supplementary trials in four publications that unfortunately contributed little to the elucidation of the role of physical activity sessions.^53^–^55,^ ^95^

Parental involvement. The role of parental involvement in weight management programs can only be considered in the context of the child's age. None of the seven trials that focused on adolescents included parents as primary participants of the intervention. However, three of the trials^71,^ ^75,^ ^82^ in adolescents did invite parents to one or more intervention sessions, and all three of those trials did show positive weight outcomes. Thus, parental participation may increase the likelihood of successful weight loss in adolescents.

All eight of the trials limited to children aged 12 or younger had high levels of parental involvement, as did two of the trials that included both younger children and adolescents. Due to the lack of variability we could not explore the importance of parental involvement further than concluding that weight-loss researchers consider parental involvement crucial for successful weight loss in young children. Parental involvement took many forms in the trials with high levels of involvement. In some trials parents and children attended weight control educational sessions together,^72,^ ^78,^ ^79,^ ^88^ while others provided family therapy, ^73,^ ^74,^ ^80,^ ^81^ or parenting skills training ^83^ in addition to traditional weight control topics. In one trial the children participated only in fun, physical play sessions or family activities, while only parents received instruction in weight management.^70^

Similarly, few conclusions could be drawn from the five supplementary comparative effectiveness trials^57^–^60,^ ^96^ attempting to isolate the importance of child vs. parental involvement. Data suggest that it may be helpful to have both parents and children involved in interventions with young children. Parent training in child management principles may also be helpful with parents of young children. These conclusions, however, are tentative because they are based on only a few trials, with limited generalizability to the population of the United States.

Five of the supplementary trials (in six publications) examined the impact of varying types of parental involvement in weight loss interventions, four in younger children^56,^ ^57,^ ^59,^ ^60,^ ^96^ and one in adolescents.^58^ Among the trials in younger children, three ^56,^ ^59,^ ^96^ compared interventions involving parents or children only with those involving both children and parents, with conflicting results: two^59,^ ^96^ suggested it was most helpful to have both child and parent involved, but this was not supported by the third.^56^ The fourth supplementary trial ^57^ in younger children found that children had greater weight loss when parents were taught child management techniques in addition to weight management principles. This contrasts with one of our primary trials^83^ conducted by Golley and colleagues, which taught child management techniques to parents without enhancing weight loss. However, Golley and colleagues provided only about half of the treatment hours of the supplementary trial.

One trial^58^ in black adolescent girls explored the role of parental involvement in families categorized as lower to lower-middle class, largely single-parent households. Researchers randomized families to one of three groups: adolescents attending treatment sessions without mothers, mothers and daughters attending sessions together, and mothers and daughters attending separate, concurrent groups. Groups did not differ on any measure of weight loss, nor did the groups differ from their own baseline measures. The authors reported low attendance among mothers in this program, which suggests that the burden of attending a treatment program in these primarily single-parent families is likely quite high.

Behavior management techniques. Among the primary 18 trials, programs that included participant training and support in the use of behavioral management techniques were more likely to be successful than those that did not. None of the four trials^69,^ ^80,^ ^81,^ ^87^ that lacked instruction in behavior management techniques were successful in improving weight outcomes. Eleven of the 14 trials that taught participants to use behavioral management techniques did show group differences in BMI or other weight outcomes. These trials all appeared to provide broad advice on using these techniques for changing diet, activity, and other related behaviors.

We identified two supplementary trials in four publications^61^–^64^ comparing standard weight loss management programs without cognitive behavioral treatment or techniques with the same programs, adding behavioral management techniques. One of these, conducted by Epstein and colleagues,^61^ provided 40 hours of contact to 24 5- to 8-year-old girls and their parents over 12 months. This trial included a 5-week intensive treatment phase and once monthly maintenance contacts thereafter. Behavioral management principles were provided to parents in one of the treatment groups, but not the other. The second trial ^64^ compared a group of adolescents receiving nutrition counseling from a dietitian without behavioral management techniques with a group receiving the same nutrition counseling plus an intervention delivered over the internet. This intervention was based on the treatment methods developed by Epstein and colleagues, which included behavior management techniques. The addition of behavioral management training improved weight outcomes in both of these trials at the end of the treatment phase, although the effect was not seen in long-term followup in the trial that measured weight outcomes 21 months after the end of treatment.^64^

### Factors Influencing the Effectiveness of Behavioral Interventions (KQ5b)

Treatment effects varied by intervention setting and by intervention intensity. Residential treatment and high-intensity interventions in specialty health care treatment settings (both inpatient and outpatient) had the largest treatment effects; medium-intensity interventions in school settings had consistent, but modest effects; some low-intensity interventions in primary care or other settings have more modest effects; and, limited data from very low-intensity primary care or internet-based interventions suggest no treatment effects. We were unable to isolate other population or environmental factors that may influence the effectiveness of a treatment because of the limited number of trials and the great heterogeneity in intervention, population, and environmental factors.

## Pharmacological Agents

### Trial Characteristics

We identified seven trials (all fair- or good-quality RCTs)^97^–^103^ evaluating a pharmacological agent's effect on overweight or obesity in a total of 1,294 adolescents aged 12 to 19 years (Table 8). Five obesity treatment trials^97,^ ^98,^ ^100,^ ^101,^ ^103^ evaluated the effectiveness of 10–15 mg/day of sibutramine in 715 patients. Two trials^99,^ ^102^ evaluated the effectiveness of orlistat (120 mg three times a day) in 579 patients. All pharmacological obesity treatment trials compared the active medication plus behavioral counseling about diet and physical activity (with or without a behavioral management program) to the effects of placebo plus the same behavioral counseling. We describe weight-related and other outcomes separately from two additional trials whose primary aim was testing the effect of metformin on preventing glucose intolerance or improving insulin sensitivity in obese adolescents with additional risk factors for diabetes ^104,^ ^105^ (see Table 10).

Table 8 Characteristics of randomized clinical trials of pharmacological anti-obesity treatments among adolescents, by drug type

Source | Intervention | No. of months of drug treatment | No. of behavioral intervention sessions | Characteristics | No of study sites | Country | % Attrition | Quality^a^ | Placebo Run-in Period | Funding Source
Sibutramine
Berkowitz et al, 2003^97^ | Sibutramine (5 mg/d for 1 wk, 10 mg/d for 4 wks, then 15 mg) + BI or placebo + BI | 6 | 19 | N randomized: 82 Age: 13–17 Female: 67% | 1 | USA | 10% | Good | Yes | NIH, hospital, pharm
Berkowitz et al, 2006^98^ | Sibutramine (10 mg/day for 6 mos, then 10–15 mg/d) + BI or placebo + BI | 12 | 10 | N randomized: 498 Age: 12–16 Female: 66% | 33 | USA | 28%^b^ | Good | No | Pharm
Garcia-Morales et al, 2006^100^ | Sibutramine (10 mg/d) + BI or placebo + BI | 6 | 8 | N randomized: 51 Age: 14–18 Female: 56% | 1 | Mexico | 22% | Fair | Yes | Pharm
Godoy-Matos et al, 2005^101^ | Sibutramine (10 mg/d) or placebo | 6 | 1 | N randomized: 60 Age: 14–17 Female: 82% | 1 | Brazil | 17%^b^ | Fair | Yes | Pharm
Van Mil et al, 2007^103^ | Sibutramine (5 mg/d for 2 wks, then 10 mg/d) + BI or placebo + BI | 3^c^ | 16 | N randomized: 24 Age: 12–17 Female: 54% | 1 | Netherlands | 17%^b^ | Fair | No | NR
Orlistat
Chanoine et al, 2005^99^ | Orlistat (120 mg, TID) + BI or placebo + BI | 12 | 18 | N: 539 Age: 12–16 Female: 67% | 32 | USA & Canada | 35% | Good | Yes | Pharm
Maahs et al, 2006^102^ | Orlistat (120 mg, TID) + BI or placebo + BI | 6 | 7 | N: 40 Age: 14–18 Female: 67% | 1 | USA | 15% | Fair | No | University supported

Abbreviations: BI - behavioral intervention (with or without a behavioral management program); TID - three times daily; NR - not reported; Pharm-pharmaceutical; NIH-National Institute of Health.

a: Quality criteria are described in Appendix B Table 1.

b: Attrition rate was different between the intervention and control groups.

c: Patients were treated with BT + sibutramine or placebo for 3 mos. and then BT alone for 3 mos.

Table 10 Randomized, placebo-controlled, clinical trials evaluating pharmacological agents among special populations of obese children and adolescents and reporting weight outcomes

Source | N randomized Study design Country | Population Length of study | Intervention Drug dose | Baseline BMI | BMI results
Srinivasan et al, 2006^105^ | N = 28 Cross-over RCT Australia | Obese children and adolescents ages 9–18 years with clinical suspicion of insulin resistance (fasting insulin: glucose > 4.5 or acanthosis nigricans) 12 months | A: Metformin for 6 months, then placebo for 6 months B: Placebo for 6 months, then metformin for 6 months Metformin dose: gradually increased (over 3 wks) up to 2 g/day vs. placebo | Total sample: 35.2 ± 5.1 kg/m^2^ (not reported by study group) | ΔΔ BMI SDS* -0.12 p=0.005 ΔΔ BMI -1.26 kg/m^2^ p=0.002
Freemark et al., 2001 ^104^ | N =32 RCT USA | Obese adolescents ages 12 to 19 years with fasting insulin concentration > 15 μU/mL; and ≥ 1 first- or second-degree relative with type 2 DM 6 months | IG: Metformin CG: Placebo Metformin dose: 500 mg, twice per day | IG: 41.5 ± 0.9 CG: 38.7 ± 1.3 (p < 0.05) | Δ BMI SDS IG: -0.12 CG: 0.23 p< 0.02 Δ BMI IG: -0.5 kg/m^2^ CG: 0.9 kg/m^2^ p-value NR

Abbreviations: BMI - Body mass index; DM - Diabetes mellitus; IG - intervention group; CG - control group; RCT - randomized controlled trial

* ΔΔ BMI = Δ BMI_IG_ - Δ BMI_CG_

Participants in the sibutramine and orlistat trials all met some type of BMI-based criteria for obesity (either above the age- and sex-specific 95 to 97^th^ percentile or above a BMI of 30 kg/m^2^), and mean BMI was typically 35 to 38 kg/m^2^ at baseline. Most trials excluded those at or above the midpoint for Class III (morbid) obesity (BMI exceeding 44 kg/m^2^) and those who had type I or type II diabetes mellitus. The sibutramine trials also generally excluded patients who had cardiovascular disease or hypertension. About two-thirds of participants in these trials were females. The majority of trials did not report race/ethnicity of participants. However, in the two largest multi-center RCTs, almost half of the sibutramine patients were racial/ethnic minorities,^98^ as were one-quarter of orlistat patients.^99^ The sibutramine trial included 21 percent Black, 16 percent Hispanic, and 7 percent other nonWhite patients. The orlistat trial included 17 percent Black and 7 percent participants of other race-ethnicity. A small (n=52) sibutramine trial conducted in Mexico could have applicability to adolescents of Mexican heritage living in the United States.^100^

The minimal behavioral intervention provided to all participants consisted of advice to follow a calorie-restricted diet (e.g., 500 kcal/day deficit) and meet physical activity goals (e.g., at least 30 min of aerobic activity per day). All but one trial^101^ also included a behavior management program, ranging in intensity from seven to 19 sessions with a dietitian, psychologist, or psychiatrist. Family members attended behavioral management sessions in only two of the seven trials.^97,^ ^103^ The length of drug therapy lasted for either 3, 6, or 12 months (in one, four, and two trials, respectively). In the single trial evaluating 3 months of drug therapy (sibutramine), we report the follow-up results at 6 months. No other trials reported followup results describing weight patterns after the pharmacologic treatment ended.

Of the six trials that reported the source of funding, all but one trial was funded by the pharmaceutical industry, either completely or partially. Two of these pharmaceutically sponsored trials were large (about 500 participants), multi-center RCTs (over 30 study sites) conducted in the United States and Canada. One evaluated sibutramine^98^ and the other evaluated orlistat.^99^ The remaining trials randomized much smaller samples (n = 24 to 82), were conducted at single sites, and reported outcomes after only six months of treatment.

Additional details on study and participant characteristics are presented in Appendix C ^†^, Table (3) ^†^.

Study design and quality. All included studies were double-blinded, placebo-controlled RCTs of fair- or good- quality (see Appendix H ^†^ for quality criteria). Most trials used appropriate randomization methods and took explicit measures to conceal allocation assignment. In all of the trials, intervention and control groups were similar at baseline for age, sex, and anthropometric characteristics. Descriptions of drug protocols were clear. Descriptions of behavioral interventions were generally adequate, but much less detailed than trials evaluating behavioral interventions. Adherence to medication protocols (measured by pill counts) was 80 percent or higher in the majority of the trials. Adherence was slightly lower (72 to 73 percent) in the large multi-center orlistat RCT. In contrast, most of the trials did not report how the behavioral intervention program was supervised, whether it was delivered as intended, or any data on adherence to diet, physical activity, or other behaviors. Most of the trials specified that outcomes were assessed by personnel blinded to treatment status.

Attrition rates ranged from 10 to 35 percent. Notably, both of the large, multi-center trials had fairly high attrition. Overall attrition was 35 percent in the large orlistat trial. In the large sibutramine trial, the attrition rate was 28 percent overall and was differential between groups (24 percent in the sibutramine group and 38 percent in the control group, p=0.001). All of the trials analyzed main weight outcomes among the intent-to-treat (ITT) or modified ITT population. The modified ITT population included any participant who had at least one post baseline efficacy measurement. Missing values were replaced using the LOCF method in most trials and/or a linear mixed-effects model for repeated measures over time. One trial^100^ excluded 10 percent of patients, even in the modified ITT population analyses, because they dropped out before one month.

### Short-term (6–12 month) Weight Outcomes With Sibutramine Treatment (KQ1)

Five trials reported outcomes 6 or 12 months after starting sibutramine treatment (in seven publications) (Table 9).^97,^ ^100,^ ^101,^ ^103,^ ^106,^ ^107^ One small trial (n=24) evaluated 3 months of a behavioral intervention plus sibutramine (10 mg) or placebo treatment, followed by 3 months of a behavioral intervention alone.^103^ Based on our calculations, BMI was not reduced more in those receiving sibutramine plus a behavioral intervention compared with placebo treatment plus a behavioral intervention. Both groups had similar, modest (-0.8 kg/m^2^ to -1.4 kg/m^2^) mean reduction in BMI at 6 months. All three trials reporting weight outcomes immediately after 6 months of treatment with sibutramine plus a behavioral intervention found a statistically significant difference between the intervention and control groups, favoring a greater reduction in BMI in the group treated with sibutramine.^97,^ ^100,^ ^101^ Among patients treated with sibutramine plus a behavioral intervention, the mean reduction in BMI ranged from -3.2 kg/m^2^ to -3.6 kg/m^2^. In contrast, the mean reduction in BMI among patients treated with placebo plus behavioral therapy ranged from -0.9 kg/m^2^ to -1.8 kg/m^2^. Budd and colleagues. 2007^106^ presented a secondary analysis of the data from one of these trials,^97^ reporting outcomes separately for the 34 Black and 45 White participants. At month six, there were no statistically significant differences in the outcomes between racial groups. This trial, however, was not designed to have adequate power to detect differences between racial groups.^†^

Table 9 Results of randomized controlled trials of pharmacological anti-obesity treatments among adolescents, by drug type

Source | N | Baseline BMI (kg/m^2^) | Treatment months | Change BMI (kg/m^2^) p value | Physiological Outcomes | | Adverse Events
Sibutramine
Berkowitz et al, 2003^97^ | 43 39 | I: 37.5 ± 4.0 C: 38.0 ± 3.6 | 6 | -3.2^a^ -1.5^a^ p=0.001^b^ | WC: SD LDL: NS HDL: NS TG: NS FPG: NS | Insulin: NS HOMA: NS Heart Rate: SD^e^ Systolic BP: SD^e^ Diastolic BP: NS | Adverse Events: NS
Berkowitz et al, 2006^98^ | 368 130 | I: 36.1 ± 3.8 C: 35.9 ± 4.1 | 12 | -2.9 -0.3 p < 0.001 | WC: SD LDL: NS HDL: SD TG: SD FPG: NS | Insulin: SD HOMA: SD Heart Rate: SD^e^ Systolic BP: SD^e^ Diastolic BP: SD^e^ | Adverse Events: NS SAE: NS d/c med: NS Growth: NS Maturation: NS
Garcia-Morales et al, 2006^100^ | 26 25 | I: 35.1± 5.3 C: 36.6 ± 5.2 | 6 | -3.4 (-2.5, -4.2) -1.8 (-0.9, -2.6) P< 0.005* | WC: NS LDL: NS HDL: NS TG: NS | FPG NS Heart Rate: SD^e^ Systolic BP: NS Diastolic BP: SD^e^ | Adverse Events: NS d/c med: NS Maturation: NS Growth: NS
Godoy-Matos et al, 2005^101^ | 30 30 | I: 37.5 ± 3.8 (f) 37.6 ± 4.3 (m) C: 35.8 ± 4.2 (f) 37.4 ± 1.9 (m) | 6 | -3.6 ± 2.5 -0.9 ± 0.9 p < 0.001 | WC: SD LDL: NS HDL: NS TG: NS FPG: NS | Insulin: NS Heart Rate: NS Systolic BP: NS Diastolic BP: NS | SAE: NS d/c med: NS Other: SD
Van Mil et al, 2007^103^ | 12 12 | I: 30.1 ± 4.5 C: 33.3 ± 5.0 | 3 + 3 mos f/u^c^ | -0.8^d^ -1.4^d^ NR | % Fat Mass: NS Heart Rate: NS | Systolic BP: NS Diastolic BP: NS | Adverse Event: NS d/c med: NS Other: SD
Orlistat
Chanoine et al, 2005^99^ | 357 182 | I: 35.7 ± 4.2 C: 35.4 ± 4.1 | 12 | -0.55 +0.3 p < 0.001 | WC: SD Other Adiposity: SD LDL: NS HDL: NS TG: NS | FPG: NS Insulin: NS Heart Rate: NS Systolic BP: NS Diastolic BP: SD^f^ | Growth: NS Maturation: NS Other: SD
Maahs et al, 2006^102^ | 20 20 | I: 39.2 ± 1.2 C: 41.7 ± 2.6 | 6 | -1.3 ± 1.6 -0.8 ± 3.0 NS | % Fat Mass: NS LDL: NS HDL: NS | TG: NS FPG: NS Insulin: NS | Other: SD

a: Calculated based on average BMI at baseline and average percentage change in BMI for each group (I: -8.5% ± 6.8%, C: -4.0% ± 5.4%).

b: Based on comparison of percent change in BMI between groups

* result of ANOVA testing interaction between treatment group and time

c: Patients were treated with BT + sibutramine or placebo for 3 mos and then BT alone for 3 mos.

d: calculated based on differences reported baseline to 3 mos and 3 mos to 6 mos.

e: Relative increased rate over time in sibutramine group compared to placebo group

f: Relative reduction in rate over time in orlistat group compared to placebo group

Abbreviations: IG - Intervention group; CG - Control group; BT - Behavioral Treatment, NS - not significant; NR - not reported; WC - Waist circumference; LDL - Low-density Lipoprotein; HDL- High-density Lipoprotein; TG - triglyceride; FPG - Fasting plasma glucose; BP - Blood pressure; SD - statistically significant difference; SAE - Serious adverse events; HOMA - Homeostasis model assessment of insulin sensitivity; d/c - discontinue.

The single large trial that reported weight outcomes after 12 months of sibutramine plus a behavioral intervention also found statistically significant results in favor of the sibutramine group.^98^ The mean reduction in BMI in the sibutramine group was -2.9 kg/m^2^ compared to -0.3 kg/m^2^ in the control group (p <0.001). As noted, this trial had higher attrition in the placebo control group (38 percent) than the sibutramine group (24 percent, p = 0.001), reducing our confidence in these findings. BMI measures over time were also analyzed using a linear mixed-effects model to predict missing values. In these analyses, the mean change in BMI between treatment and control groups was statistically significantly different at all study visits from week 1 through month 12. The difference between the changes in BMI z-scores was also statistically significant. In this trial, the mean change in body weight (± SE) at month 12 was -6.5 ± 0.31 kg in the sibutramine group versus 1.9 ± 0.56 kg in the placebo group (difference -8.4 kg, or 18.5 pounds (CI: -9.7,-7.2 kg); p < 0.001 by linear mixed-effects model).

### Maintenance of Weight Changes After Sibutramine Treatment (KQ2)

No trials reported on maintenance of weight loss after sibutramine was discontinued.

### Adverse Effects of Sibutramine Treatment (KQ3)

Adverse effects results are reported in Table 9. A more detailed account is included in Appendix C ^†^ Table 3. All sibutramine trials evaluated the effects on heart rate and systolic and diastolic blood pressure. Three of the five sibutramine trials found statistically greater increases in heart rate and systolic and/or diastolic blood pressure in the sibutramine group compared to the control group after 6 or 12 months of treatment, but differences were small in magnitude. In the 12-month, multi-center sibutramine trial, tachycardia occurred more commonly in the sibutramine than the control group (12.5 percent vs. 6.2 percent, p = 0.049). Withdrawals due to tachycardia, however, were similar between groups.

None of the sibutramine trials reported statistically significant differences between groups in the overall rates of having any adverse event, any serious adverse event, or discontinuation due to adverse events. In the large, 12-month sibutramine trial, serious adverse events were reported by 2.7 percent of patients in the sibutramine group and less than 1 percent of the control group. Only one of these events (excessive nausea and vomiting) was thought to be related to sibutramine. Two trials examined growth and maturation, including the 12-month, multi-center trial. Neither trial found a significant difference between the groups. Abdominal complaints and constipation were also found to be statistically higher in the sibutramine group in the shorter-term trials.

### Other Beneficial Outcomes With Sibutramine Treatment (KQ4)

Physiological outcomes in the sibutramine trials are also presented in Table 9. Three of the four trials that reported changes in waist circumference found statistically significant differences favoring the sibutramine groups. In these three trials, the sibutramine groups reduced the waist circumference on average by seven to eight cm. In contrast, the placebo groups reduced waist circumference on average by two to three cm (p <0.001 for all three trials). Four trials reported^†^ the effects on lipid profiles or glycemic parameters at 6 or 12 months followup. Of these, statistically significant differences were only reported in the large, multi-center, 12-month trial,^96^ which found greater improvements in HDL cholesterol, triglycerides, serum insulin, and HOMA, compared to the placebo group. Differences in LDL cholesterol and fasting serum glucose were not statistically different between groups.

### Components of Effective Sibutramine Treatment (KQ5a)

Data were largely insufficient to explore the importance of specific treatment components. Based on the limited number of trials, shorter treatment (3 as compared with 6 or 12 months) may be related to reduced beneficial effects on BMI. There are other possible explanations for these between trial differences, however, such as lack of placebo run in or differences in population or setting.

### Factors Influencing the Effectiveness of Sibutramine (KQ5b)

Data were insufficient to explore the importance of population or environmental factors.

### Short-term (6–12 month) Weight Outcomes With Orlistat Treatment (KQ1)

Two trials reported the weight outcomes after 6 or 12 months of orlistat therapy plus a behavioral intervention and results were mixed. The large (n=539), multi-center trial evaluating 12 months of orlistat therapy found a statistically significant difference between the change in BMI, favoring the orlistat plus a behavioral intervention group (-0.55 kg/m^2^ vs. 0.3 kg/m^2^, p < 0.001).^99^ The absolute mean body weight increased in both groups during the 12-month trial, but increased less in the orlistat group (0.53 kg vs. 3.14 kg, p <0.001). Attrition in this trial was quite high (33 to 34 percent), but analyses of primary weight outcomes included over 98 percent of randomized participants and replaced missing data using the LOCF method. Also, baseline characteristics were not different for completers or those who dropped out within each group. Nevertheless, the high level of attrition in the trial somewhat limits its validity. A smaller trial (n=40) that evaluated the effects of six months of orlistat plus a behavioral intervention found that the orlistat group had a larger BMI reduction than the control group (-1.3 kg/m2 vs. -0.8 kg/m2), but this difference was not statistically significant.^102^

### Maintenance of Weight Changes After Orlistat Treatment (KQ2)

No trials reported on maintenance of weight loss after orlistat was discontinued.

### Adverse Effects of Orlistat (KQ3)

Rates of serious adverse effects and discontinuation of therapy due to adverse effects were low in both trials and were not reported to be statistically different between groups. In the Chanoine and colleagues trial,^99^ one or more serious adverse effects occurred in 3 percent of both groups. Discontinuation of therapy due to a serious adverse event occurred among 12 of 357 (3 percent) of orlistat patients and 3 of 182 (2 percent) patients in the placebo group. In the orlistat group, only one event was thought to be study-related: asymptomatic cholelithiasis in a 15-year-old female who had lost 15.8 kg by the time of the event. In the Maahs and colleagues trial,^102^ 2 of 20 patients in the orlistat group and 0 of 20 patients in the placebo group withdrew from the trial due to adverse effects. One suicide death occurred in the orlistat group to a patient who was under a psychiatrist's care. No deaths occurred in the placebo group.

Gastrointestinal (GI) side effects were very common among patients taking orlistat. Chanoine and colleagues reported that among patients taking orlistat: 50 percent reported fatty or oily stools; 20 to 30 percent reported oily spotting, oily evacuation, abdominal pain, fecal urgency, or flatus with discharge; 10 to 15 percent experienced soft stool, nausea, and increased defecation. Notably, 9 percent of orlistat patients reported fecal incontinence, compared with less than 1 percent of placebo patients. Chanoine and colleagues also reported that the GI side effects were mostly mild- to moderate-intensity and led to discontinuation of treatment among only two percent of orlistat patients. In the smaller 6-month orlistat trial, Maahs and colleagues also reported that numerous adverse gastrointestinal effects occurred significantly more frequently in the orlistat group than the placebo group, including: soft stools, oily spotting, fatty or oily stools, oily evacuation, liquid stools, cramping, flatus with discharge, and fecal incontinence. Soft stools, oily spotting, fatty or oily stools, oily evacuation, and liquid stools all occurred in over 50 percent of patients treated with orlistat. Flatus with discharge occurred in 20 to 47 percent of patients treated with orlistat (varying by study month), in contrast to 0 percent in all but the first month for the control group. Fecal incontinence occurred in 6 to 13 percent of the orlistat group at each month, in contrast to 0 percent of the control group during any month. The authors report that the oily spotting, fatty or oily stools, and cramping improved more over time in the orlistat group than in the placebo group.

Both orlistat trials measured vitamin A, D, and E levels and reported that levels were not different between groups. In the Maahs trial, quality of life measured using four different scales showed no statistically significant differences between groups over time. Possible lack of blinding in the outcome assessors, however, could have influenced these results. No between-group differences in growth, bone mineral density, and sexual maturation were reported.^99^

### Other Beneficial Outcomes of Orlistat Treatment (KQ4)

Chanoine and colleagues reported that both waist circumference and hip circumference decreased significantly more in those receiving orlistat and a behavioral intervention, compared with placebo plus behavioral intervention controls, at 12 months (p=0.01 for both in least squares mean (LSM) analysis). The LSM reduction for waist and hip were -2.67 and -1.52 cm, respectively, for the orlistat group, compared with -0.89 and -0.10 cm in the control group. In a subset of patients evaluated with dual-energy x-ray absorptiometry (DEXA), patients in the orlistat group lost significantly more fat mass than patients in the placebo group (-2401 g vs. -380 g; p =0.03). In contrast, percent body fat at 6 months was measured using bioelectrical impedance analysis in the Maahs trial, and no statistically significant differences were found between groups. Levels of LDL, HDL, TG, FPG, and insulin were measured in both Orlistat trials, and no significant differences were found between groups in either trial. The Chanoine and colleagues trial, however, reported a small reduction in diastolic blood pressure in the orlistat group (-0.51 mm Hg), compared to an increase in the placebo patients (+1.30 mm Hg; p=0.04). Change in systolic BP was similar in both groups and not statistically different.

### Components of Effective Orlistat Treatment (KQ5a)

Data were insufficient to explore the importance of specific treatment components.

### Factors Influencing the Effectiveness of Orlistat (KQ5b)

Data were insufficient to explore the importance of population or environmental factors.

### Metformin Treatment in Obese Patients at High-Risk for Type 2 Diabetes

We identified two small, fair-quality trials (a RCT and a cross-over RCT; total randomized N = 60) that reported weight outcomes after 6 months of metformin therapy among obese children or adolescents with additional risk factors for developing type 2 diabetes mellitus (Table 10). Both trials compared the effect of metformin to placebo therapy, either with minimal^105^ or no^104^ concurrent behavioral counseling intervention.

### Short-Term (6–12 month) Weight Outcomes with Metformin Treatment (KQ1)

Both trials found statistically significant differences between groups for BMI or BMI SDS at 6 months, with results favoring the metformin group. Results should be interpreted with caution, however, because analyses in these trials included only patients who completed the trial (attrition rates were 9 and 21 percent), which could have caused bias.

### Maintenance of Weight Changes with Metformin (KQ2)

No data were reported on maintenance of weight loss after metformin was discontinued.

### Adverse Effects of Metformin (KQ3)

Trials were limited in their ability to detect adverse effects due to small sample size and limited duration. Neither trial reported any serious adverse events. One trial specifically reported that no episodes of vomiting or lactic acidosis occurred. Serum lactate, liver, and renal function parameters were reported as remaining normal or not different between groups in both trials. In both trials, some patients were reported to have nausea which, in three cases, required a 25 to 50 percent dose reduction in order to continue in the trial.

### Other Beneficial Outcomes of Metformin Treatment in High-risk Obese Adolescents (KQ4)

One of the trials^105^ found statistically significant improvements favoring the metformin group for waist circumference and subcutaneous adipose tissue, but no difference for visceral abdominal adipose tissue. These parameters were not reported in the other trial. Both trials reported improvements in fasting glucose and insulin, either between groups or only within the metformin group. Neither trial found statistically significant differences between groups for insulin sensitivity when using minimal model analyses, glucose effectiveness, acute insulin response disposition index, or glucose disposal. No lipid parameters were found to be statistically different between groups in the only trial that measures them.^104^

## Bariatric Surgeries

We identified 18 fair- or poor-quality case series in 22 publications^108^–^130^ reporting on weight change, complications, and other outcomes from various bariatric surgeries performed in a total of 612 children and adolescents. Overall quality of reporting was fair at best. Many case series are limited in value because they only represent the experience of single institution (and often a single surgeon). Relying on retrospective medical record review limited the completeness of outcomes measurement and the consistency with which other variables, such as comorbidities, were determined on all patients. Further, considerable attrition occurred in all case series and results were reported for complete cases only. These results likely represent a best case scenario. We calculated intention to treat results, assuming those that were eligible, but lost to followup, experienced no weight reduction. We report both complete cases (CC) and intention-to-treat (ITT) here, where possible, to provide a range of realistic estimates. Completed cases are the reported decreases in BMI for those patients returning for followup, while the Intention-to-Treat analyses (ITT, indicated with an asterisk on Table 11) reflect the conservative assumption that patients not returning for followup had no change in BMI.

Table 11 Bariatric surgery weight outcomes

| | | Change in BMI, kg/m^2^ unless noted
Study | Population characteristics | Baseline BMI, mean (range) | Short-term 6–12 months | | Medium-term 1–5 yrs | | Longer-term ≥ 5 yrs
Laparoscopic Adjustable Gastric Band
Angrisani 2005^114^Band brand NR | N: 58 Age: 17.96 ± 0.99 yr Female: 81% | 46.1 ± 6.31 kg/m^2^ | 1 yr | 10.2 kg/m^2^ (n=48/52) 9.4 kg/m^2^ * (n=52/52) | 3yr | 8.3 kg/m^2^ (n=37/42) 7.3 kg/m^2^ * (n=42/42) | 5yr | 11.2 kg/m^2^ (n=25/33) 8.5 kg/m^2^ * (n=33/33
7 yr | 16.4 kg/m^2^ (n=10/10)
Nadler 2007 ^111^Lap-Band^®^ | N: 53 Age: 15.9 yr (13–17) Female: 77.4% | 47.6 ± 6.7 kg/m^2^ | 6 mo | 8.1 kg/m^2^ (n=33/53) 5.0 kg/m^2^ * (n=53/53)
Dolan 2003^115,116^Fielding^130^Lap-Band^®^ | N: 17 Age: Median 17 yr (12–19) Female: 82.4% | (calculated): 43.1 kg/m^2^ (30.3–70.5) | 1 yr | 10.1 (n=17/17) | 2 yr | 12.7 kg/m^2^ (n=11/17) 8.2 kg/m^2^ * (n=17/17)
Abu-Abeid 2003^126^Lap-Band^®^ | N: 11 Age: 15.7 yr (11–17) Female: 72.7% | 46.6 kg/m^2^ (38–56.6) | | 14.5 kg/m^2^ Mean 1.9 yr (6 mo – 3 yrs)
Silberhumer 2006^129^Widhalm 2004^117^ Lap-Band^®^ and SAGB^®^ | N: 50 Age: 17.1 yrs (9–19) Female: 62% | 45.2 kg/m^2^ (32.5–76.7) | | 12.6 kg/m^2^ Mean 2.9 yr (4 mo – 7 yrs)
Yitzhak 2006^114^ SAGB^®^ | N: 117 total; n= 60 ≥ 36 mo follow-up Age: 16 yr (9–18) Female: 70% | 43 kg/m^2^ (35–61) | Self-reported weight measures
Gastric Bypass/Other procedures
Lawson 2006 ^112^ Lap RYGB | N: n=30 weight n=36 harms Age: Mean NR (13–21 yr) Female: NR | 56.5 ± 5.2 kg/m^2^ (41.9–95.5) | 1 yr | 20.7 ± 8.1 kg/m^2^ (n=30/30)
Collins 2007 ^98^ Stanford 2003^110^ Lap RYGB | N: 11 Age: 16.5 ± 0.2 yrs (15–18) Female: NR | 50.5 ± 2.0 kg/m^2^ (42–66) | No valid outcomes available
Sugerman 2003^108^ Gastric Bypass 91% | N: 33 Age: 16 ± 1 yr (12.4–17.9) Female: 57.6% | 52 ± 11 kg/m^2^ (38–91) | 1 yr | 16 kg/m^2^ (n=31/32) 15.5* kg/m^2^ (n=32/32) | | | 5 yr | 19 kg/m^2^ (n=20/24) 15.8 kg/m^2^ * (n=24/24)
Sugerman 2003^108^ Gastric Bypass 91% | N: 33 Age: 16 ± 1 yr (12.4–17.9) Female: 57.6% | 52 ± 11 kg/m^2^ (38–91) | 1 yr | 16 kg/m^2^ (n=31/32) 15.5* kg/m^2^ (n=32/32) | | | 10yr | 18 kg/m^2^ (n=14/18) 14 kg/m^2^ * (n=18/18)
14 yr | 14 kg/m^2^ (n=6/9) 9.3 kg/m^2^ * (n=9/9)
Soper 1975^120^ Anderson 1980^121^ Open RYGB; Horizontal gastroplasty | N: 18 Age: Median 19 yr (≤ 20 yrs) Female: 55.6% | Median weight: 147.0 kg | 6 mo | % BW lost 15% (n=17/18) 14.2%* (n=18/18)
1 yr | 30% (n=14/18) 23.3%* (n=18/18)
Mason 1995^119^ VBG | N: 47 (2 with Prader Willi) Age: 18.1 ± 1.84 yr Female: 68% | 48.4 kg/m^2^ | | | | | 5 yr | 12.2 kg/m^2^ (n=25/35) 8.7 kg/m^2^ * (n=35/35)
10 yr | 9.2 kg/m^2^ (n=14/19) 9.2 kg/m^2^ * (n=19/19)
Capella 2003^118^ Open RYGB; VBG | N: 19 Age: 15.6 yrs (calc)(13–17) Female: NR | 49 kg/m^2^ (38–67) | 19 kg/m^2^ Mean 5.5 yrs (1 mo –10 yrs)
Strauss 2001^122^ Open RYGB | N: 10 Age: (15–17 yr) Female: 70% | 52.4 kg/m^2^ (calc) | | 46.8 kg/m^2^ Mean 5.75 yrs (7 mo – 13 yrs)
Barnett 2005^113^ Open RYGB; VBG; JIB | N: 14 Age: 15.7 yrs (13–17) Female: 57% | 55.1 ± 14.8 kg/m^2^ | | 24 kg/m^2^ Mean NR (9 mo – 22 yrs)
Breaux 1995^124^ Open RYGB; VBG; BPD | N: 22 Age: 15.3 yr (calc)(8–18) Female: 59% (calc) | Without sleep apnea 56.4 kg/m^2^ Sleep apnea 67.8 kg/m^2^ | | Without Sleep Apnea 20.9 kg/m^2^ Mean 4.2 yr (6 mo – 16.6 yrs)
With Sleep Apnea 23.8 kg/m^2^ Mean 2.7 yr (9 mo – 10.1 yrs)
Rand 1994^125^ Open RYGB; VBG | N: 34 of 39 possible Age: 17 ± 2 yrs (11–19) Female: 79% | 47 ± 7 kg/m^2^ | Self reported weight
Papadia 2007^128^ BPD | N: 68 Age: 16.8 yrs Female: 76.5% | 46 kg/m^2^ | | | 78% EWL Mean 11 yrs (2 – 23 yrs)
Tsai 2007^109^ | N: 566 procedures Age: 12–19 yrs (96.4% were 15–19) Female: 78.6% | NA | No weight outcomes reported

* Indicates intention-to-treat calculation.

Abbreviations: BW - body weight; EWL - excess weight loss; RYGB - Roux-en-Y gastric bypass; VBG - vertical banded gastroplasty; BPD - Biliopancreatic diversion

To reflect differences in invasiveness and the way case series were reported, we grouped the surgeries into two main types: 1) laparoscopic adjustable gastric banding (LAGB); 2) Roux-en-Y gastric bypasses (RYGB), vertical-banded gastroplasty (VBG) and other bypass procedures. Where possible, we distinguish individual case series that focus on a single surgical procedure (e.g. RYGB or VBG) and indicate whether RYGB was performed via laparoscope or laparotomy.

Of the six case series of laparoscopic adjustable gastric banding (LAGB), three reported short-term weight changes (6–12 months) after surgery,^111,^ ^114,^ ^115^ four reported medium-term weight changes (1 to 5 years) after surgery,^111,^ ^114,^ ^115,^ ^126,^ ^129^ and one reported longer term post-surgery weight changes (5 and 7 years) (Table 11).^114^ One additional LAGB case series that relied on retrospective self-reported weight changes after surgery was used to estimate shorter term adverse effects, as these were retrieved from medical records, but not weight outcomes.^127^

Of two case series of Roux-en-Y gastric bypasses performed by laparoscope,^110,^ ^112^ only one reported usable weight-change data, and these were short-term (12 month).^112^ The other series provided only data useful for adverse effect estimates (Table 11).^110^

Nine case series included open Roux-en-Y Gastric Bypass (RYGB), vertical-banded gastroplasty (VBG), and other surgeries, but only four of these reported post-operative weight outcomes at the same time point for all patients. Two reported short-term (6 to 12 month) weight changes after open RYGB.^108,^ ^120^ An older series of primarily open RYGB cases reported 3 year and 4-year weight outcomes,^124^ and one case series that provided 1-year RYGB outcomes also reported 5-, 10-, and 14-year outcomes for a decreasing subset of eligible patients.^108^ A single case series of VBG reported outcomes at 5 and 10 years only.^119^ The remaining five case series that included open RYGB, VBG, jejunal-ileal bypass and biliopancreatic diversion combined weight outcomes from different lengths of followup for different patients, which varied from a minimum of 13 months to 10 years or more.^113,^ ^118,^ ^122,^ ^125,^ ^128^ Results from all case series are reported in Table 11.

### Laparoscopic Adjustable Gastric Banding (LAGB)

Six case series, detailed in nine publications,^111,^ ^114,^ ^115,^ ^117,^ ^126,^ ^127,^ ^129,^ ^130^ reported on LAGB performed primarily outside the United States on or after January 1996 in a total of 306 children and adolescents. The single surgical series conducted in the United States was a recent, fair-quality prospective study conducted in a university center with a comprehensive bariatric surgery program.^111^ This was the only study reporting on race/ethnicity. Among the 53 adolescents undergoing LABG in this trial, 81 percent were White, 13 percent were Hispanic and 6 percent were Black. Across the body of literature, most LAGB patients were adolescents, with a mean age for participants in each study from 15.7 to 18.0 years (age range from 9 to 19 years). Most surgical patients were females (n=223, 73 percent) and most met NIH adult criteria for morbid obesity (BMI > 40 or ≥35 with at least one-comorbidity).^40^ Most patients had also previously failed conservative weight management approaches. Across studies, the mean BMI prior to surgery ranged from 43.1 kg/m^2^ to 47.6 kg/m^2^, which roughly corresponds to a mean weight at baseline between 129.19 kg (284 pounds) and 135 kg (297 pounds). In studies reporting comorbidities,^126,^ ^127,^ ^129^ 23 percent to 62 percent had at least one comorbidity (see Table 12). Hypertension, diabetes, and dyslipidemia were the most commonly cited. In two studies, 17 percent of LAGB patients had sleep apnea.^114,^ ^127^ In two other studies, five percent had asthma.^127,^ ^129^

Table 12 Other outcomes for bariatric surgical procedures

Study | Failure | Resolution of comorbidities | Adverse events
Laparoscopic Adjustable Gastric Band
Angrisani 2005^114^ Band brand NR | ≤ 25% EWL at 5 yrs: 20% (5/25) | NR | Mortality: None Laparotomic conversion: 1.7% (1/58) Overall postoperative complications: 10.3% (6/58) Band slip: 1.7% (1/58) | Gastric pouch dilation: 3.4% (2/58) Intragastric migration: 5.2% (3/58) Band removal: 10.3% (6/58) Conversion to gastric bypass or BPD: 5.2% (3/58)
Nadler 2007^111^ Lap-Band^®^ | NR | NR | Perforated appendicitis within 10 days of surgery: (1.9% 1/53) Band slip: 3.8% (2/53) Hiatal hernia: 3.8% (2/53) Wound infection: 1.9% (1/53) | Mild hair loss: 9.4% (5/53) Iron deficiency: 7.5% (4/53) Nephrolithiasis, cholelithiasis: 1.9% (1/53) Gastroesophageal reflux: 1.9% (1/53)
Dolan 2003^115,116^ Fielding^130^ Lap-Band^®^ | NR | NR | Band slip: 5.9% (1/17) Leaking port: 5.9% (1/17)
Abu-Abeid 2003^126^ Lap-Band^®^ | NR | Amenorrhea: 100% High triglycerides: 100% (2/2) Abnormal cholesterol: 0% (0/1) | Perioperative complications: 0% Late complications: 0%
Silberhumer 2006^129^ Widhalm 2004^117^ Lap-Band^®^ and SAGB^®^ | 6% (3/50) had EWL < 25% after at least 1 yr of follow-up | Diabetes mellitus II: 80% (4/5) Hypertension: 50% (6/12) Dyslipidemia: 100% (4/4) Asthma: 100% (3/3) Cholecystolithiasis: 100% (3/3) | Perioperative complications: 0% Dislocated port: 2% (1/50) Band slip: None
Yitzhak 2006#^127^ SAGB^®^ | NR | 100% resolution of all co-morbidities. Hypertension: 3/3 Diabetes Mellitus: 2/2 Asthma: 3/3 Obstructive sleep apnea: 10/10 | Mortality: 0% Major post-operative complications: 0% Band slip: 10% (6/60) Band removal: 3.3% (2/60)
Gastric Bypass/Other procedures
Lawson 2006^112^ Lap RYGB | 6.7% (2/30) in 1st year regained weight-up to 50% of weight lost. All patients were still overweight to severe obesity at 1 yr follow-up. | NR | 2/36 were converted to an open procedure (5.6%) Minor complications (readmission < 7 days): 9/36 (25%) Moderate complications (readmission or sequelae for 7–30 days): 4/36 (11%) | Severe complication (sequelae for more than 30 days): 2/36 (5.6%), which includes 1 death 9 months post-operative due to complications from severe infectious colitis. Non-compliant with 12 mo. office visit: 23% (9/39)
Collins 2007^110^ Stanford 2003^123^ Lap RYGB | NR | Diabetes: 50% (3/6) Hypertension: 50% (3/6) Obstructive sleep apnea: 100% (2/2) no longer required constant positive airway pressure at night Polycystic ovarian syndrome: 67% (2/3) All co-morbidities: 30.1% resolved | Postoperative bleeding: 3/11 (27.3%) with 1 of these needing laparoscopic reevaluation. Marginal ulcer: 2/11 (18.2%) (1 and 18 mo postoperative) Non-compliant with vitamin regimen: 18.2% (2/11)
Sugerman 2003^108^ Gastric Bypass 91% | 15% (5/33) regained all or most of weight lost at 5–10yrs | Diabetes Mellitus II: 100% (1/1) Hypertension: 80% (8/10) Sleep apnea: 100% (6/6) | [underlined: Late complications]: 21% (7/33) Incisional hernia: 18.2% (6/33) Bowel obstruction: 3% (1/33) Conversions to another type of bypass due to late weight gain or severe protein-calorie malnutrition: 6% (2/33) | [underlined: Early complications]: Pulmonary embolism: 3% (1/33) Major wound infection: 3% (1/33) Minor wound infection: 12% (4/33) Stomal stenoses: 9% (3/33) Marginal ulcers: 12% (4/33) No patients had evidence of impaired sexual or physical maturation.
Soper 1975^120^ Anderson 1980^121^ Open RYGB; Horizontal GP | NR | NR | Revision: 5.6% (1/18) Wound infection: 12% (3/25*) Respiratory difficulty: 12% (3/25*) Thrombophlebitis: 4% (1/25*) Upper gastrointestinal bleed: 4% (1/25*) | Urinary tract infection: 4% (1/25*) Protracted vomiting: 4%(1/25*) Incisional hernia: 16% (4/25*) *n=25, which includes 7 Prader-Willi patients
Mason 1995^119^ VBG | NR | NR | Mortality: None Revisions: 8.5% (4/47)
Capella 2003^118^ Open RYGB; VBG | NR | NR | Mortality: None Revisions: 10.5% (2/19) Cholecystectomy: 5.3% (1/19)
Strauss 2001^122^ Open RYGB | 3 women who became pregnant regained 13–45 kg | NR | Protein-calorie malnutrition/micronutrient deficiency: 10% (1/10) Cholecystectomy: 20% (2/10) Small bowel obstruction 10 yrs postoperative: 10% (1/10) Incisional hernia: 10% (1/10)
Barnett 2005^113^ Open RYGB; VBG; JIB | NR | Hypertension: 100% (5/5) Asthma: 66.7% (2/3) Sleep apnea: 100% (2/2) Diabetes: 100% (1/1) Hypothyroidism: 0% (0/1) | Mortality: None Dumping syndrome: 14.3% (2/14) Surgical site infection: 7.1% (1/14) Hypoglycemia: 7.1% (1/14)
Breaux 1995^124^ Open RYGB; VBG; BPD | NR | Sleep apnea: 100% (11/11) | Mortality: 2 deaths at 15 mo and 3.5 yrs postoperative. Incisional hernia: 5% (1/22) Postoperative laryngeal edema: 5% (1/22) | Gallstones: 5% (1/22) Kidney stones: 5% (1/22) Nutritional deficiencies: 23% (5/22) Revision: 4.5% (1/22)
Rand 1994^125^ Open RYGB; VBG | NR | NR | 2 cholecystectomies 1 abdominal panniculectomy No other AE reported. 3 had surgical revisions-2 were scheduled for revisions.
Papadia 2007^128^ BPD | NR | Hypertensive: 92% (27/33) Dyslipidemic: 100% (11/11) Hyperglycemic: NR Diabetes mellitus II: 100% (2/2) | Reoperations: 19 in 14 patients (14/68=21%) Mortality long-term: 4.4% (3/68) Protein malnutriiton 1–10 yrs post surgery: 16% (11/68) Immediate complication: 1.5% (1/68)
Tsai 2007^109^ | NR | NR | Mortality: None Major complications: 5.5%78.3% (119/152) of major complications were respiratory

Abbreviations: AE- adverse events; EWL - Excess weight loss; RYGB - Roux-en-Y gastric bypass; VGB - Vertical banded gastroplasty; BPD - Biliopancreatic diversion; JIB - Jejunoileal Bypass; NR - Not reported; GP - Gastroplasty

### Short-term (6–12 month) Weight Changes After LAGB (KQ1)

Three studies ^111,^ ^114,^ ^115^ reported mean decrease in BMI for the cohort at discrete time-points (6 months, 12 months after surgery, presumably for all participants who were eligible during this duration of followup). Two of these studies also provided data on the same cohort at longer term followup.^114,^ ^115^ Two case series averaged data for participants across a broad duration of followup,^126,^ ^129^ while a third reported weight data based on retrospective self-report only.^127^

Loss to followup and the small number of cases (n=122) make any conclusions drawn from these case series tentative. Available data, however, suggest following gastric banding, patients experienced an average BMI decrease of 5.0 kg/m^2^ (ITT) to 8.1 kg/m^2^ (CC) at 6 months and 9.4 kg/m^2^ (ITT) to10.2 kg/m^2^ (CC) at 1 year. Based on one study in 17 patients,^115^ 77 percent achieved a BMI less than 35 at 1 year.

### Maintenance of Weight Changes After Laparoscopic Adjustable Gastric Banding (KQ2)

Four studies reported weight outcomes measured 2 or 3 years after LAGB and results were in similar range at both time points.^114,^ ^115,^ ^126,^ ^129^ Mean decrease in BMI ranged from 8.2 kg/m^2^ (ITT) to 14.5 kg/m^2^ (ITT) at 2 years, and 7.3 kg/m^2^ (ITT) to 12.6 kg/m^2^ (ITT) at 3 years. In the two studies that also measured BMI at 12 months,^114,^ ^115^ ITT analysis suggests that on average, some weight is regained at 2 years (1.9 kg/m^2^) and at 3 years (2.1 kg/m^2^). While experience certainly varies among individuals, these data are roughly consistent with plots of repeated weight measures in individual patients from several case series that suggest BMI decreases after surgery to its nadir at 12–18 months in most patients and then stabilizes or slightly rebounds in those with longer term followup.^115,^ ^126^ The single study with results at time points beyond 3 years suggests that mean BMI decrease was at least maintained at 5 years (ITT analysis), based on followup of 25 individuals.^114^ Estimates for 7 years followup represent only 10 individuals.

### Adverse Effects of LAGB (KQ3)

There was no peri- or post-operative mortality or major morbidity among 306 children and adolescents undergoing LAGB.^111,^ ^114,^ ^115,^ ^117,^ ^126,^ ^127,^ ^129,^ ^130^ We confine estimates of adverse effects to the four largest case series (defined as those series representing at least 50 patients). In one large case series,^114^ a number of patients required reoperations (6/58, 10.3 percent) for band removal or repositioning and one of 58 patients required conversion to laparotomy. In a second large case series, 13.3 percent (8/60) had band slippage or removal.^127^ In the third series, a dislocated port was reported (1/50), but no band slippage. In the fourth series (from the United States), nutrition-related issues (mild hair loss in 5/53 or iron deficiency in 4/53) were reported, along with other less common issues occurring in one or two patients, such as hiatal hernia, gastroesophageal reflux, and wound infection. (Table 12)

### Other Beneficial Outcomes of LAGB (KQ4)

Across the three LAGB studies reporting whether comorbidities “resolved” post-surgery,^126,^ ^127,^ ^129^ 6/13 with hypertension, 8/9 with type II diabetes, 6/7 with dyslipidemia, and 20/20 with sleep apnea were reported as resolved, as were 9/9 with asthma. Two studies also reported some improvements in quality of life, self-esteem, body image, and satisfaction with having chosen surgery, although the quality and timing of these measurements are not clear.^127,^ ^129^

### Components of Effective LAGB Surgery (KQ5a)

Data were inadequate to examine this question.

### Factors Influencing the Effectiveness of LAGB Surgery (KQ5b)

Data were inadequate to examine this question.

### Roux-en-y Gastric Bypass (RYGB), Open Vertical-banded Gastroplasty (VBG), and Other Bariatric Surgeries

Eleven fair- or poor-quality case series reported weight and other beneficial outcomes in 41 adolescents after laparoscopically performed RYGB,^110,^ ^112^ in 51 adolescents after open RYGB,^108,^ ^120^ and in 47 adolescents after VBG.^119^ The remaining six case series (n=167 youth) provided primarily adverse effects data,^113,^ ^118,^ ^122,^ ^124,^ ^125,^ ^128^ as weight outcomes were either self-reported or averaged across very different post-operative time periods. All but two of these series (one evaluating RYGB^122^ and one evaluating biliopancreatic diversion^128^) were further limited by mixing different types of surgeries. Inpatient adverse effects but not weight outcomes, associated with 566 open, primarily RYGB, procedures in youth have also been reported from the Healthcare Cost and Utilization Project (HCUP) Nationwide Inpatient Sample.^109^

### Short-term (6–12 month) Weight Changes After RYGB, VBG, and Other Bariatric Surgeries (KQ1)

Two fair-quality case series in three publications^110,^ ^112,^ ^123^ address laparoscopic RYGB performed in the United States in 41 adolescents and young adults (aged 13 to 21 years). Mean BMI before surgery was 50.5 kg/m^2^ (SD, 2.0 kg/m^2^) in one group (n=11) ^110^ and 56.5 kg/m^2^ (SD, 5.2 kg/m^2^) in the other (n=30).^112^ Few other patient data were reported, although patients met or exceeded NIH adult criteria for bariatric surgery and had failed previous medical attempts at weight loss. Comorbidities were reported in the smaller case series. Diabetes (6/11), hypertension (6/11), sleep apnea (2/11), and hepatic steatosis (5/11) were most common.^110^

Laparoscopic RYGB. Measured weight outcomes were available in one of these two series^112^ and limited to 30 of 36 patients that had accrued sufficient time post-surgically (although 3/6 not included were actually lost to followup). Among these 30 patients, mean decrease in BMI at 12 months was 20.7 kg/m^2^ (SD, 8.1 kg/m^2^) and individual BMI reductions ranged from 3.3 kg/m^2^ to 43.5 kg/m^2^. Treatment failures in the first year (those who regained up to 50 percent of the weight lost) were reported in two of 30 patients.

Open RYGB. A large fair-quality case series conducted in the United States of 33 adolescents undergoing bariatric surgery at a single institution over 20 years reported on short-term outcomes at 12 months (but also reported outcomes 5, 10, and 14 years after surgery).^108^ Most cases (28/33) underwent open gastric bypass, two had laparoscopic gastric bypass, and the remaining three underwent vertical banded or horizontal gastroplasty. Eligible patients were 12 to18 years of age (mean age 16 years) and met NIH bariatric surgery criteria for adults. Almost 60 percent were female, 82 percent were White, and 15 percent were Black. The mean pre-operative BMI of these patients was 52 kg/m^2^ (SD 11 kg/m^2^, range 28 to 91). Hypertension was present in 30 percent (10/33), sleep apnea in 18 percent (6/33), and diabetes mellitus II in 3 percent (1/33) of patients. At 1 year, mean decrease in BMI was 15.5 kg/m^2^ according to intention-to-treat analysis (ITT) and 16 kg/m^2^ according to complete cases (CC). The only other case series followed primarily open gastric bypass bariatric surgeries performed in 18 genetically normal adolescents (under aged 20 years, median age 19) between 1969 and 1973 at a single university hospital pediatric surgery department in the United States.^120^ Median pre-operative weight in eight female and 10 male patients was 147 kg. At 6 months, the median percentage of body weight lost was 14 percent (ITT). At 10 to 15 months, the median percentage of body weight lost was 23 percent (ITT). Complete case analysis at 10–15 months was slightly more optimistic (30 percent body weight lost).

### Maintenance of Weight Changes after RYGB, VBG, and other Bariatric Surgeries (KQ2)

Laparoscopic RYGB. Longer-term data on maintenance are not available on laparoscopically performed RYGB.

Open RYGB or VBG. The one large case series, conducted in the United States, of 33 adolescents also reported on longer term outcomes (5, 10, and 14 years) after surgery.^108^ Based on complete cases, mean BMI reductions appear to be maintained or enhanced at 5, 10, and 14 years, compared with results at one year. Based on ITT analyses, mean BMI reduction is maintained at 5 years, with some regain of weight suggested by 10 to 14 years. By these time points, however, only a limited number of participants (less than 20) were eligible for followup due to the recency of the surgery and about one-third of these were not actually measured. Long-term (5 or more years) estimates of BMI reduction are very tentative, due to small numbers and the considerable difference between CC and ITT estimates, which vary by 3 to 5 kg/m^2^. While these data provide estimates of average effects at various time points after surgery, they are not very instructive in estimating weight maintenance for individuals, particularly given the drastic reduction in those eligible for long-term followup. In terms of treatment failures, however, five patients of 33 regained most or all of their weight 5 to 10 years after surgery. One patient with horizontal gastroplasty maintained weight loss after 15 years, but then regained the weight.^108^

One case series provided longer term outcomes after VBGs, which were performed from 1980-1994 in 47 adolescents aged 14 to 20 years. Mean BMI was decreased 8.7 kg/m^2^ (ITT) to 12.2 kg/m^2^ (CC) at 5 years and 6.8 kg/m^2^ (ITT) to 9.2 kg/m^2^ (CC) after 10 years.^119^ These results are limited due to unclear methods that may have mixed self-reported and measured weights. These results provide a point of comparison only, since this procedure is not currently widely used.

The other case series of RYGB, VGB, or other gastroplasties averaged weight outcomes from individuals measured over a broad duration of followup rather than at the same post-operative time points.^113,^ ^118,^ ^122,^ ^124^ These averaged weight changes measured at short-term, medium term, and longer term followup were generally across more than 10 years. A recent study on biliopancreatic diversions performed in 68 Italian adolescents over 29 years similarly averaged weight outcomes measured between 2 and 23 years after surgery.^128^ While these studies reported their outcomes for the mean followup time (5 or more years), the combination of weight outcomes over such different time periods of followup makes them of limited use in estimating weight outcomes.

### Adverse Effects After Bariatric Surgeries (KQ3)

Laparoscopic RYGB. Among 47 adolescents undergoing laparoscopically performed RYGB, around 39 percent experienced some short-term complications during the first 12 months.^110,^ ^112^ More than 25 percent (13/47) experienced minor complications (requiring a special test, treatment, endoscopy, or hospital readmission for seven days or less). Moderate complications (unanticipated intensive care unit admission, reoperation, or hospital readmission for more than seven days) occurred in about 14 percent (5/36) of patients. Severe complications (threat to life or major organ system failure) were uncommon (2/36), although one death occurred due to infectious colitis. Two of 36 patients undergoing laparoscopic RYGB had to be converted to an open procedure. During the first post-operative year, noncompliance with recommendations for multivitamin use or for clinical monitoring occurred in one-quarter (11/47) of adolescent surgical patients.

Open RYGB. Among 33 adolescents who primarily underwent open RYGB,^108^ 30 percent (10/33) experienced early complications, including one pulmonary embolus, one major wound infection, one minor wound infection, three stomal stenoses requiring endoscopic dilatation, and four marginal ulcers requiring medical therapy. In 21 percent of patients (7/33), late complications requiring surgical treatments primarily included incisional hernias, and one of 33 patients required conversion to another type of bypass due to severe protein calorie malnutrition. In other case series^113,^ ^118,^ ^124,^ ^125^ of a mixture of 89 cases undergoing open gastric bypasses and gastroplasties, two deaths were reported at 15 months and 3.5 years post-operatively: it is difficult to determine whether deaths outside the immediate post-operative period are surgery-related. Other complications included cholecystectomies or gallstones reported in six patients, nutritional deficiencies in five patients, and dumping syndrome or hypoglycemia in three patients.

Since outcomes from case series were not systematically assessed, and relied on retrospective review of medical records or patient recall, absolute rates for complications cannot be determined from these data or from another poor quality case series.^122^ However, data from the Nationwide Inpatient Sample on 566 bariatric surgeries (90 percent gastric bypasses) performed in adolescents from 1996 through 2003 found no in-hospital deaths, but did find major complications in 5.5 percent of cases. Over three-quarters (119/152) of major complications were respiratory, including aspiration, postoperative pulmonary edema, pulmonary insufficiency, acute respiratory failure, prolonged ventilation, tracheostomy, or pneumonia.^109^

Bilio-pancreatic diversion. In a retrospective medical record review of 68 biliopancreatic diversions performed in Italy in those under aged 18 years, while immediate complications were uncommon (1/68) longer term complications were not.^128^ Long-term mortality was 4.4 percent (3/68), protein malnutrition within 1 to 10 years post-operatively occurred in 11 of 68 (16 percent) patients, and 14 patients underwent 19 reoperations. These data are consistent with findings that BPD incurs higher complication and mortality rates.

### Other Beneficial Outcomes After RYGB (KQ4)

Very limited data on patients after laparoscopic or open RYGB suggest decreasing need for hypoglycemic medications in 4/7 of those with diabetes, resolution of hypertension in 11/16 and no longer needing continuous positive airway pressure or resolution in 8/8 patients with sleep apnea.^108,^ ^110^ The reported resolution of comorbidities in a series including various bariatric surgeries, including RYGB, confirms that sleep apnea resolves in all patients (13/13).^113,^ ^124^ Very limited data supports benefits for hypertension (5/5), asthma (2/3), and diabetes (1/1).^113^

### Components of Effective Bariatric Surgery (KQ5a)

Since the absolute number of bariatric surgeries in adolescents is small, particularly when categorized by surgical type, there are no good data that examine the effectiveness of specific factors, such as surgeon training, experience, or institutional expertise on outcomes, particularly harms. Other potentially important issues include the intensity and professional disciplines involved in both pre-operative evaluation and post-operative followup management.

### Factors Influencing the Effectiveness of Bariatric Surgery (KQ5b)

Similarly, limited data prevent the examination of potentially important population or environmental factors, including degree of overweight, medical and psychological history, family factors (including parental overweight and history of parental bariatric surgery), previous nonsurgical weight loss attempts, and compliance with post-operative management.