# Methods

## Terminology

A glossary of terms used throughout this report can be found at the end of the report^*^. The first occurrences of terms that are included in the glossary are italicized in the body of the text.

Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/childweight/chweight.pdf.

## Key Questions and Analytic Framework

We developed five key questions (KQ) and an analytic frame work (Figure 3) in conjunction with a Technical Expert Panel to evaluate the effectiveness and safety of behavioral, pharmacological, and surgical treatments for overweight and/or obese children. KQ1 evaluates the effectiveness of interventions in reducing or stabilizing weight using short-term (6–12 months since enrolling in treatment), while KQ2 focuses on the maintenance of BMI improvements through medium-term (between 1 to 5 years since enrollment and at least 12 months since treatment ended) or longer term measurements (5 or more years since enrollment). KQ3 assesses adverse effects of behavioral, pharmacological, and surgical interventions. Other beneficial outcomes arising from the interventions and were captured in KQ4. KQ5 considers whether specific program components and population or environmental factors can be identified for effective weight control programs.

Figure 3. Analytic framework and key questions

[underlined: Key Questions (KQ)]

1 Do weight management interventions lead to BMI reduction or stabilization in children and adolescents who are obese (≥95th BMI percentile) or overweight (85–94th BMI percentile)?
  (a) Behavioral Interventions
  (b) Pharmacological Interventions
  (c) Surgical Interventions
2 Do weight management interventions help children and adolescents who were initially obese (≥95th BMI percentile) or overweight (85–94^th^ percentile) maintain BMI improvements after the completion of an active intervention?
  (a) Behavioral Interventions
  (b) Pharmacological Interventions
  (c) Surgical Interventions
3 Are there harms associated with weight management interventions to help children and adolescents reduce or stabilize BMI who are obese (≥95th BMI percentile) or overweight (85–94th BMI percentile)?
  (a) Behavioral Interventions
  (b) Pharmacological Interventions
  (c) Surgical Interventions
4 Are there other beneficial outcomes to weight management interventions in children and adolescents who are obese (≥95th BMI percentile) or overweight (85–94th BMI percentile) (i.e., improvements in diet or physical activity or reduction in risk factors, such as lipid level, insulin resistance, etc.)?
5 If effective behavioral weight management interventions are found (see KQ1),
  (a) are there specific components of the interventions that affect the effectiveness of the programs?
  are there population or environmental factors that affect the effectiveness of the programs?

## Literature Search Strategy

In 2006, NICE published a comprehensive report which addressed the prevention and management of obesity in adults and children.^2^ Relevant portions of this report served as a basis for the primary search for the literature included in the current report. The NICE report only included orlistat and sibutramine. Therefore, we used another good-quality review of pharmacological treatments^39^ as the basis for our search for pharmacological treatments. We conducted update searches in Ovid MEDLINE®, PsycINFO, Database of Abstracts of Reviews of Effects, the Cochrane Database of Systematic Reviews, Cochrane Central Register of Controlled Trials, and Education Resources Information Center from 2005 (2003 for pharmacological treatments) to December 11, 2007, to identify literature that was published after the search dates of the these reports (Appendix A *). The literature search and reports^2,^ ^39^ were supplemented by hand-searching the reference lists of other good-quality reviews of childhood obesity treatment,^31,^ ^33,^ ^47^–^49^ suggestions from experts, and reviewing reference lists of included trials. We did not search for data from non-peer-reviewed sources.

## Article Review and Data Abstraction

Two investigators independently reviewed 2355 abstracts and 338 articles for inclusion in each key question. Discrepancies were resolved by consensus. Detailed inclusion/exclusion criteria can be found in Appendix G ^†^. Briefly, the study population included overweight or obese 2 to 18 year-olds. We excluded studies of children with idiosyncratic weight management issues. Trials were required to be designed to promote weight loss or maintenance and report weight outcomes of at least 6 months, although we included immediate harms when these were also reported. Interventions of mazindol and jejunal-ileal bypass were excluded because they are no longer used in current practice. Behavioral and pharmacology trials were required to have a minimum intervention or control group with at least 10 participants in each arm. Trials included for KQ5 were allowed to compare active treatments to help clarify the role of specific program components. Systematically selected case series were permitted for surgical studies (for both short-term and maintenance efficacy as well as harms of treatment). Only controlled trials (RCTs and CCTs) were included for efficacy (short-term and maintenance) of behavioral and pharmacological treatments. Weight management programs reporting pre-specified adverse events resulting in death, hospitalization, or need for urgent medical or psychiatric treatment were included to assess harms (KQ3) for all treatment modalities, even if they did not report one of our specified weight outcomes. In addition, we abstracted all reports of harms or potential harms in included studies. We would have included large comparative cohort studies to evaluate harms of behavioral and pharmacological treatments if they had been available.

† Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/childweight/chweight.pdf.

Other beneficial outcomes (KQ4) were only examined using trials that were included for KQ1 (short-term efficacy) or KQ2 (maintenance efficacy). The presence of any other beneficial outcome was abstracted, including impact on comorbidities if reported.

One investigator abstracted data from included studies into evidence tables. A second investigator verified the evidence tables' content. All studies were quality-rated independently by two investigators using established design-specific criteria (Appendix H ^†^), with discrepancies resolved by consensus or a third investigator. Poor quality studies were excluded, except in the case series of bariatric surgeries, where all available case series in adolescents were included due to very limited data. Five trials of behavioral interventions and one of pharmacological treatment were excluded because they did not meet our quality criteria.

Treatment intensity was categorized by hours of contact as follows: very low intensity (less than 10 hours); low (10 to 25 hours); medium (26 to 75 hours), high (over 75 hours). Weight outcomes were categorized as short-term (6 to 12 months since beginning treatment), medium term (between 1 and 5 years after beginning treatment and at least 12 months after ending active treatment), or longer term (5 or more years after beginning treatment). Maintenance was evaluated where possible using multiple measurements in the same individuals at least 12 months after an active intervention ended or by using single post-baseline measurements in the medium or longer term. For behavioral interventions, short-term weight outcomes were those that were either measured immediately after treatment ended (post-treatment) or some months after active treatment ended, but still within the first 12 months after entering treatment (followup). Weight outcomes were abstracted as reported for a variety of different methods: endpoint BMI, absolute change in BMI from baseline, percent change in BMI from baseline, absolute change in BMI SDS from baseline, endpoint weight, and absolute change in weight from baseline.

We used two approaches to determine which specific intervention components we examined for KQ5. First, based on prior literature we identified several factors that may affect weight outcomes in behavioral interventions. These include whether or not studies included organized physical activity sessions,^50^ behavioral modification^31,^ ^51^ (for dietary and physical activity), or involved parents or families in addition to the child (clarifying extent to which parental involvement is important, for what ages).^33,^ ^51,^ ^52^ Next, we examined the distribution of treatment elements between successful and unsuccessful treatment trials. To do this, we coded participants' age (C=only included children aged 12 and under; A=only included those aged 10 and older; B=Age range included both younger children and adolescents) and the three main components of behavioral interventions as follows: (1) presence of organized physical activity sessions (0=did not provide organized physical activity session, 1=provided organized physical activity); (2) use of behavioral modification principles (0=no or minimal use of behavioral modification principles,1=applied behavioral modification principles in treatment); (3) family involvement (0=no parental involvement beyond consent/receiving materials; 1=parent attended 1 to 3 sessions, less intensive involvement than child; 2=parent was also a primary recipient of treatment).

For our second approach to examining important treatment components, we identified comparative treatment trials where the comparison could illuminate the importance of one of the components described above: organized physical activity, extent of behavioral modification principles, and family involvement. We examined all studies meeting the same inclusion criteria as those used for KQ1 and KQ2, except that no minimal-treatment control group was required. We found three trials comparing programs with and without organized physical activity sessions,^53^–^55^ five with varying forms of family involvement,^56^–^60^ and two comparing programs with and without cognitive-behavioral therapy techniques.^61^–^64^ Trial details can be found in Appendix C ^†^ Table 2.

## Literature Synthesis

We cover three major types of interventions in this review: behavioral, pharmacological, and surgical. We address each of the five key questions listed in our analytic framework within the framework of each type of intervention.

Where possible, data were synthesized using quantitative methods. For most questions, however, we relied on qualitative synthesis due to significant heterogeneity in setting, age range, intervention approach, weight outcome reported, and timing of outcome reporting among the limited number of studies available for each overall type of intervention. To more clearly articulate the magnitude of weight or weight change in pounds, we modeled typical cases. In these cases, we used growth charts published by the CDC^4^ to estimate average height for weight and to translate between percentile scores, BMI, and percent overweight (based on CDC-published 50^th^ percentile scores for weight or BMI). We also employed on-line calculators provided at the CDC web site^65,^ ^66^ for calculating BMI and BMI percentiles. To convert BMI to pounds for an illustrative child of a given age and height, we used the following formula: Pounds = (BMI*inches^2^)/703.

Studies reported a variety of weight outcomes including BMI, BMI percentile scores, BMI standard deviation or z-scores, and percent overweight. All of these measures have strengths and limitations. BMI is reliably measured and widely used, but can be problematic when averaging BMI change over a wide age range, where younger children would naturally show smaller changes. Percentile scores are helpful when describing weight change in children of many ages because they are a measure of relative overweight, rather than absolute weight. The limitation of percentile scores, however, is that there can be a large range in the highest extremes (above the 99^th^ percentile).

To avoid the difficulties with an limited upper range of BMI percentile scores, many researchers report BMI standard deviation scores (SDS, also known as z-scores) or measures of “percent overweight.” Both of these are measures of the relative degree of overweight similar to percentile scores, but without a truncated upper limit. BMI SDS is calculated as the number of standard deviation units above or below the median, based on statistically derived curves.^67^ BMI SDS requires the use of published computer programs that access reference data and formulae, such as that published by the CDC.^68^ Percent overweight is calculated by the simple formula:

100*(child's BMI/50^th^ percentile BMI for child's age and sex).

This method was used chiefly in earlier studies, published before programs were available to calculated BMI SDS. The disadvantage of using percent overweight scores is that they do not account for the known weight distribution. When given multiple weight outcomes, we selected them according to the following hierarchy: (1) BMI (this was the most commonly reported outcomes and the outcome used for meta-analyses), (2) BMI percentile, (3) BMI SDS, and (4) percent overweight.

We focused on the change in BMI from baseline as the preferred measure of weight change when it was available. In many cases, the standard deviations of the change in BMI was not reported and could not be calculated or estimated. In those cases, we could not consider quantitative pooling of results.

### Quantitative Synthesis

For the behavioral interventions, we conducted meta-analyses of short-term (KQ1) and maintenance (KQ2) outcomes within each setting. Twelve^69^–^80^ of the sixteen trials reporting short-term weight outcomes were included in the meta-analysis for KQ1. Five were in school settings,^69^–^72,^ ^75^ and there were two each in specialty health care^73,^ ^74^ and primary care^77,^ ^78^ settings. The final trial in this analysis was the only included trial conducted on-line.^76^ It was, therefore, not statistically combined with other trials, although it appears on the visual display of the meta-analysis for qualitative comparison purposes.

Four^72,^ ^73,^ ^78,^ ^81^ of the five trials reporting maintenance outcomes were included in the meta-analysis of KQ2, grouped by setting. Two of these trials were conducted in specialty health care settings,^73,^ ^81^ and one trial each was conducted in school^72^ and primary care^78^ settings; all of these are presented on the summary display but not all were statistically combined with other trials. Three ^72,^ ^73,^ ^78^ of the trials reported both short-term and maintenance outcomes and are included in both meta-analyses.

If mean change scores from baseline for each group were not reported, we calculated an unadjusted difference between the mean baseline and mean followup scores for each group using simple subtraction. Standard deviations (SDs) of the change scores were reported in five trials with post-treatment outcomes and one trial with followup outcome. In addition, three authors who did not report them in published articles provided us with these unpublished data.^69,^ ^76,^ ^80^ We calculated standard deviations for trials that did not report them. Baseline BMI is highly correlated with post-treatment and follow-up BMI, and we had to take this correlation into account when calculating the standard deviations of the change scores. In order to estimate the degree of correlation, we examined data from a trial^70^ that reported both the SDs of the change scores (which we were attempting to calculate) and the SDs of the baseline and post-treatment BMIs (which we would use to calculate of the SDs of the change scores). From this trial, we ascertained that the correlation between the baseline and post-treatment score was approximately 0.90. Therefore, we assumed a correlation of 0.90 for the remaining trials and calculated SDs of BMI change using the following formula:

SD_baseline-followup_ = sqrt(SD^2^ _baseline_ + SD^2^ _followup_ - 2*0.90*SD_baseline_*SD_followup_).

When given standard errors rather than standard deviations, we calculated standard deviations by multiplying the standard error by the square root of n. When given symmetric confidence limits rather than standard deviations, we determined the standard deviation using the following formula:

Std Dev = (CI width)(√n)/2*(1.96)

We used random effects models because the trials varied considerably along many dimensions that would impact both baseline BMI (e.g., age, minimum overweight inclusion criteria) and change in BMI (e.g., intensity of intervention, comprehensiveness of treatment program). All meta-analyses were conducted using the “metan” procedure of Stata 9.2 with the “random” option, and then confirmed the results using RevMan 4.2. Forest plots are taken from our RevMan output.