# Introduction

## Scope and Purpose

This review examines available behavioral *, pharmacological, and surgical weight management treatments for overweight and/or obese children and adolescents (defined as those between 2 and 18 years of age). Our work builds on our previous review conducted for the United States Preventive Services Task Force in 2005 and leverages a recently released report by the National Institute for Health and Clinical Excellence (NICE).^1^ Since this review focuses on treating children and adolescents who are already overweight or obese, it does not address programs preventing the development of overweight and obesity among children and adolescents in the general population. Prevention, however, is a critical component of an overall public health strategy to address the dramatic increase in childhood and adolescent overweight in the United States. Preventive programs have been addressed by several comprehensive reports elsewhere.^1^–^3^

* Words found in the glossary are italicized on first mention.

## Background

### Definition and Measurement of Overweight and Obesity in Children and Adolescents

In contrast to colloquial usage, where obesity and overweight generally refer to culturally undesirable body size (“being fat”), these terms represent specific conditions with unique criteria in the medical and scientific literature. While obesity is a condition of excess body fat (adiposity), which is associated with adverse health states and risk for future disease, the medical definition of obesity in children and adolescents is not as straight forward as for adults. At present, there is no universally accepted definition that distinguishes children with normal or healthy weight from those whose level of adiposity is unhealthy. While the presence of obesity in some children and adolescents is obvious with simple observation, it is difficult to determine when a child who is not obviously overweight faces health risks from adiposity. In the absence of a clear, health-based definition of obesity, children are instead categorized as “overweight” and “obese” based on how they compare with a normative sample of children of the same age and sex.

Body mass index (BMI) is the most common measure used to define overweight and obesity in children, adolescents, and adults. BMI is a height-adjusted weight measure that is calculated from measured weight (in kg) and height (in meters) as kilograms divided by meters-squared (kg/m^2^). Clinicians compare a child's BMI to that of other children of the same age and sex to determine a percentile score based on published norms, such as those developed by the Centers for Disease Control and Prevention in the United States.^4^ (see Figures 1 and 2) Because BMI naturally changes with age, percentile scores based on age- and sex-specific norms are used to determine overweight and obesity and monitor growth and development in children and adolescents. Over time, changes in percentile scores can show clearly when a developing child has become fatter or slimmer. Thus, while BMI might increase in an overweight growing child, a decrease in percentile score would indicate a positive outcome, as their growth in height outstripped their weight gain Table 1 shows the BMI-based terms that denote different levels of excess weight in children and adolescents and compares them to terms in adults. We've provided adult terminology and classification both for context, to help the reader interpret BMI values reported in children and adolescents, and because the categorizations may be valid for older adolescents who have achieved their adult height. Figures 1 and 2 also provide comparisons between various height (inches or centimeters) and weight (pounds and kilograms) measures and absolute BMI, BMI percentiles, and BMI standard deviation scores (SDS). The Expert Committee (A committee convened by the American Medical Association (AMA) and co-funded in collaboration with the Department of Health and Human Services' Health Resources and Services Administration (HRSA) and the CDC) recommends using the term “overweight” to refer to children with BMI in the 85^th^ to 94^th^ percentiles for their age and sex. They recommend the term “obese” to refer to children with BMI at or above the 95^th^ percentile for their age and sex or with a BMI at or above 30, which is the adult standard for defining obesity.^5^ These definitions were originally derived from population norms rather than health states, and research continues to focus on clarifying the health risks associated with various definitions of overweight and obesity in children, adolescents, and adults. These and other definitions can be found in the glossary.

Table 1 Definition of overweight and obesity terms for children and adolescents, and adults

Children and adolescents | | Adult
Overweight | 85^th^–94^th^ percentile BMI (age-sex specific) | Overweight ^46^ | BMI 25–29 kg/m^2^
Obese | ≥ 95^th^ percentile BMI or BMI ≥ 30 kg/m^2^, whichever is lower^5^ | Obesity Class I Class II Class III (also called morbid, severe) | BMI 30–34.9 kg/m^2^ BMI 35.0–39.9 kg/m^2^ BMI ≥ 40 kg/m^2^
Severe obesity^5^ | > 99^th^ percentile BMI | NIH criteria for bariatric surgery in adults^40^ | BMI >40 kg/m^2^ Or BMI >35 kg/m^2^ with co-morbidities

Figure 1. Illustrative BMI percentile chart with table of weight and BMI standard deviation score for selected percentiles: Boys

Figure 2. Illustrative BMI percentile chart with table of weight and BMI standard deviation score for selected percentiles: Girls

Although it is not a direct measure of adiposity, BMI-for-age percentile measures in boys and girls correlate reasonably well with percentile rankings of directly measured percent body fat (correlations generally between 0.78 to 0.88).^6^ Obesity (primarily defined as BMI ≥ 95th percentile) has also been correlated with childhood health consequences and with risk factors for obesity-related morbidity in adults.^7^–^9^ Since BMI is an imperfect measure of body fat, however, categorizing children and adolescents as obese based on BMI definitions can be problematic. Recent data from the Bogalusa Heart Study found that 35 percent of children aged 5 to 17 years with BMI > 95^th^ did not have excess body fat.^10^ At or above the 99^th^ percentile, however, almost all (94 percent) had excess adiposity. Those with the highest BMI percentiles (≥ 99^th^) were also much more likely to have two or more cardiovascular risk factors (59 percent) compared with those in the broader group at or above the 95^th^ percentile (39 percent). Noting these differences, experts have recently proposed distinguishing the “severely obese”, defined by the 99^th^ percentile, as those in particular need of clinical evaluation and treatment.^11,^ ^12^

An absolute BMI level can indicate very different weight states in children and adolescents of different ages, as is clear from Table 2 and Figures 1 and 2. A BMI of 20 would categorize an 8 year old as obese, but would categorize a 16 year old as normal weight. Absolute BMI levels may be more informative for clinical and research outcomes than percentiles in children and adolescents, particularly those above the 95^th^ percentile, where there can be a broad range of actual BMIs (and therefore weights). Above the 99^th^ percentile, BMI measures can overlap with BMI levels used to define obesity in adults (30 kg/m^2^). Thus, experts recommend that obesity in children and adolescents be defined as BMI ≥ 95^th^ percentile or BMI ≥ 30 kg/m^2^, whichever is lower.^12^ Since no measure is ideal for every age, many youth obesity researchers report multiple measures, including BMI, BMI percentiles, BMI standard deviation scores (SDS, also known as z-scores), or an older measure, “percent overweight.”

Table 2 BMI at 50^th^, 85^th^, 95^th^, and 99^th^ percentiles and weight in pounds for BMI of 25, 30, 35, and 40 at ages 8, 12, and 16 years

| | BMI (kg/m^2^) at percentiles* Children and adolescents | | | | Weight (lbs) at BMI levels** Adults
50^th^ Percentile for Height | | Over-weight^5^ | Obesity | Severe Obesity | Over-weight | Obesity Class I | Obesity Class II | Obesity Class III
Age (Sex) | inches | 50th | 85th | 95th | 99th | 25 | 30 | 35 | 40
8 (Male) | 50.5 | 15.8 | 17.9 | 20.0 | 25.6 | 91 | 109 | 127 | 145
8 (Female) | 50.5 | 15.8 | 18.3 | 20.7 | 26.4 | 91 | 109 | 127 | 145
12 (Male) | 58.5 | 17.8 | 21.0 | 24.2 | 31.8 | 122 | 146 | 170 | 195
12 (Female) | 59.5 | 18.1 | 21.7 | 25.2 | 33.1 | 126 | 151 | 176 | 201
16 (Male) | 68.5 | 20.5 | 24.2 | 27.5 | 33.9 | 167 | 200 | 234 | 267
16 (Female) | 64 | 20.4 | 24.6 | 28.9 | 39.1 | 146 | 174 | 204 | 233

th Estimated average height for age from 50 percentile on CDC Growth Chart “Stature-for-age percentiles: Boy (or Girls), 2 to 20 years”.

2 Pounds = (BMI × inches) /703 was used to convert from BMI to pounds.

### Prevalence of Children and Adolescents Obesity in the United States

Between the early 1970s and 2003 to 2004, the prevalence of obesity (defined as age- and sex-specific BMI ≥ 95^th^ percentile) increased three- to six-fold, depending on age, sex, and ethnicity.^13^ In 2003 to 2004, the prevalence of obesity among 6- to 19 year-old children and adolescents was approximately 16 to 18 percent.^14,^ ^15^ When children and adolescents who are overweight (defined as age- and sex-specific BMI in the 85^th^ to 94^th^ percentile) are also included, this prevalence increases to almost one in three children and adolescents identified as overweight or obese (31 to 33 percent).^13,^ ^15^ Looking at the youth with the most severe levels of obesity, 3 to 6 percent of boys aged 13 to 17 years are at or above the 99^th^ percentile. For girls, the comparable figure is 1 to 3 percent.^10^

The prevalence of obesity varies somewhat with age. Children aged 6 to 11 years have the highest prevalence of obesity (18.8 percent), compared with younger children (13.9 percent) and adolescents (17.4 percent), according to data from the 2003 to 2004 National Health and Nutritional Evaluation Survey (NHANES).^13^ Males have slightly higher prevalence of obesity for all age categories. Childhood obesity is increasing all around the world, not just in the United States. A meta-analysis calculated that the annualized change in prevalence of obesity in school children in the United States from 1971 until 2000 was approximately 0.4 percentage points per year.^16^ Twenty-three North American, Eastern European, Western European, and Asian countries reporting comparable data also showed increases in childhood obesity, with annualized changes ranging from less than 0.1 percentage points (in Finland and the Netherlands) to over 0.7 percentage points (Singapore and East Germany).^16^ The estimated prevalence of overweight (including obesity) in children and adolescents in the Americas as a whole is 27.7 percent. Europe has the next-highest estimate at 25.5 percent, then Eastern Mediterranean countries (23.5 percent), followed by countries in the West Pacific (12.0 percent) and South East Asia (10.6 percent). Prevalence of overweight and obesity are low in African nations (1.6 percent).

### High-Risk Groups for Child and Adolescent Obesity and Overweight

In the United States, minority children and adolescents are disproportionately obese and overweight at all ages.^13^ One large nationally representative study using NHANES data found that 43 percent of Mexican-American boys age 6 years or older were obese or overweight, which was higher than nonHispanic White (29 percent) and nonHispanic Black (31 percent) boys in the same age range.^15^ Native American boys are also more likely to be obese—39 percent of Native American adolescent boys in the National Longitudinal Study of Adolescent Health (Add Health) were categorized as obese in the mid-1990s, compared with 10 to 15 percent among other ethnic groups.^17^ NonHispanic White girls have lower prevalence of obesity or overweight (26 percent), compared with nonHispanic Black (42 percent), and Mexican American (39 percent) girls.^15^ These racial/ethnic disparities are consistent with prevalence figures reported by the Add Health study, which reported obesity in Black (18 percent), Hispanic (13 percent), and Native American (14 percent) adolescent girls, compared with Asian (4 percent) and nonHispanic White girls (10 percent). Statistical tests of these differences were not reported. Racial differences are also seen in the persistence of obesity into adulthood among children and adolescents aged 5 to 14 years. One study found that 65 percent of obese White girls and 84 percent of obese Black girls remained obese into adulthood. Results were similar for obese boys (71 percent of White boys versus 82 percent of Black boys).^18^

There is also clear correlation between income level and obesity prevalence in White children and adolescents. Obesity prevalence is highest in the lowest income bracket, and those with highest income levels have the lowest obesity prevalence.^19^ This correlation is less clear for Black and Hispanic ethnic groups, however, where data suggest no clear linear relationship between income and obesity.^19^

Children of obese parents have a higher risk of obesity,^20^ with children with two obese parents having the highest risk of obesity.^21^ A large-scale epidemiological study published in 1976 found that by age 17, children with two obese parents had three times larger triceps skinfold measures as those with two lean parents.^21^ Compared to children without obese mothers, children with obese mothers are three to ten times more likely to be obese themselves. White and Black children of obese mothers are three times more likely to be obese, Hispanic children of obese mothers are twice as likely to be obese, and Asian children of obese mothers may be as much as ten times more likely to be obese.^22^ In addition, maternal obesity has been associated with earlier age of obesity onset in children.^22^

### Health and Psychosocial Consequences of Child and Adolescent Obesity

Although the data on the health and psychosocial consequences of obesity in children and adolescents are almost exclusively observational, and therefore causal relationships cannot be established, there is growing evidence that childhood and adolescent obesity can have a substantial health impact.^7,^ ^9^ While most children will not experience the health consequences of persistent childhood obesity for decades, some of these consequences can occur prior to adulthood, particularly in those who are severely obese.^9^ Obese children and adolescents have a higher risk of type 2 diabetes mellitus, asthma, and nonalcoholic fatty liver disease, are more likely to have cardiovascular risk factors, such as hypertension and hyperlipidemia. These children and adolescents are also more likely to experience other adverse health-related events, such as perioperative adverse respiratory events when undergoing procedures requiring anesthesia.^7,^ ^9,^ ^23^ Obese children may be more likely to experience mental health and psychological issues, such as depression ^24^ and low self-esteem,^9,^ ^24,^ ^25^ than nonobese children. The risk of mental health issues increases with age and is higher in girls,^7^ likely reflecting the pressures of the social environment. For severely obese children, impacts on quality of life can be severe and other serious conditions such as obstructive sleep apnea, orthopedic problems, infertility, and increased intracranial pressure can occur.^7,^ ^9,^ ^11,^ ^26^

One of the greatest concerns about childhood obesity is that it may persist into adulthood.^27^ Adult obesity, in turn, has a detrimental effect on adult health^2,^ ^28,^ ^29^ and mortality.^28,^ ^30^ Other systematic reviews have examined the persistence of obesity from childhood into adulthood.^31^ Factors associated with greater persistence of obesity from childhood into young adulthood included older age and higher BMI (above the 95^th^ percentile or higher). Recent data from the Bogalusa Heart Study confirm these findings.^27^

Although it is difficult to distinguish childhood obesity's effects on morbidity and mortality independent of the effect of adult obesity, a systematic review reporting on the long-term consequences of pediatric obesity concluded that obesity-related cardiovascular disease can originate in childhood obesity.^7^ This review, and others, indicate that childhood obesity has also been associated with adverse social and economic outcomes in young adulthood.^7,^ ^9,^ ^32^

### Current Interventions for Child and Adolescent Obesity and Overweight

Behavioral intervention. Behaviorally based interventions are the first-line treatment for overweight and obesity in children and adolescents.^11^ Behavioral weight management interventions promote weight loss through modifications in diet and activity level without the use of adjuncts, such as pharmacologic agents. Typical behavioral interventions aim to modify food consumption to emphasize healthy eating and reduce consumption of high calorie-low nutrient snack foods and sugary foods and beverages. A range of approaches has been used to encourage more healthy patterns of dietary intake and physical activity, which are discussed in detail elsewhere.^5,^ ^11,^ ^33^ Behavioral interventions often involve parents or entire families, particularly for younger children. Optimally, behavioral interventions include cognitive and behavioral management techniques to help participants initiate and sustain needed lifestyle changes, and a range of approaches have been utilized.^33,^ ^34^ We refer to programs that focus on dietary counseling and brief lifestyle change advice without more extensive use of behavioral management principles as “behavioral counseling” interventions. We use the term “behavioral management intervention” to denote programs that are more extensive and include principles of cognitive and/or behavioral management. We use the term “behavioral intervention” as a general term to refer to both behavioral counseling and management interventions.

Pharmacologic treatment. A number of pharmacological agents are also being used to promote weight loss among obese adults as adjuncts to behavioral intervention. Weight loss drugs can be divided into two main categories based on their putative mechanism of action—appetite suppressants and lipase inhibitors. Appetite suppressants may be divided further based on the specific neurotransmitters they are thought to affect. Sibutramine and orlistat are the two most well studied weight loss drugs among adults. Sibutramine is a centrally acting appetite suppressant that selectively inhibits the reuptake of serotonin and norepinephrine, increasing their levels in the brain. Orlistat is a lipase inhibitor that is thought to promote weight loss by reversibly binding to the active center of the enzyme lipase, preventing digestion and absorption of some dietary fats. It also reduces the absorption of fat-soluble vitamins.

The United States Food and Drug Administration (FDA) has approved some medications for the treatment of obesity in adults. Only one medication has been approved for prescription use in obese children and adolescents (aged 12 and older). Medications not specifically approved for obesity treatment in children and adolescents may be considered for off-label use by physicians. The FDA approved the use of sibutramine and orlistat for the long-term treatment of obese adults in 1997 and 1999, respectively.^35^ In 2003, the FDA approved orlistat for treatment of overweight among pediatric populations (ages ≥ 12 years).^36^ In 2007, the FDA also approved orlistat for over-the-counter use among adults ages 18 years and older.^37^ Several other appetite suppressants are FDA-approved only for short-term treatment of overweight adults (benzphetamine, diethylpropion, phendimetrazine, and phentermine).^38^ Additional drugs that are not FDA-approved for treating overweight or obesity have been considered as potential weight loss agents such as some antidepressants (fluoxetine, sertraline, and bupropion), antiepileptic drugs (topiramate, zonisamide, lamotrigine), and the antidiabetic biguanide metformin. ^38^

A recent systematic evidence review found that numerous different drugs produced modest weight loss among adults when combined with dietary recommendations: sibutramine, orlistat, phentermine, bupropion, fluoxetine, topiramate, and probably diethylpropion.^39^ The additional weight loss attributable to these drugs has been less than five kg at 1 year. The drugs have not been compared directly against each other, and the report found no evidence that any particular drug produced more weight loss than any other. All of the drugs had side effects. Sibutramine was associated with modest increases in heart rate and blood pressure and with preventing decreases in blood pressure that may have occurred with weight loss. Orlistat is associated with numerous gastrointestinal side effects such as diarrhea, flatulence, bloating, abdominal pain, and dyspepsia.

Surgical treatment. Surgical approaches to weight loss (bariatric surgeries) have been developed to treat those in whom more conservative measures have failed. The criteria for undertaking bariatric surgery for adolescents have largely followed expert-based criteria for adults from a 1991 NIH consensus conference,^40^ although expert-based criteria for selecting severely obese adolescents for bariatric surgery have also been published.^41^ These criteria specify that surgery be considered for persons who have attained skeletal maturity with a body mass index (BMI) greater than 40 and with high-risk co-morbid conditions responsive to weight loss, such as obstructive sleep apnea or severe diabetes mellitus. Recent followup data from severely obese adults undergoing bariatric surgeries indicate reduced risk factors, such as hypertension, dyslipidemia, or incidence of type 2 diabetes, and reduced all-cause mortality (29 percent).^42^

Surgeries can induce weight loss through two means—restriction and malabsorption. Restrictive approaches reduce the stomach size to limit the amount of food that can be consumed at a single meal. Malabsorptive approaches bypass portions of the intestines to limit the proportion of calories absorbed from ingested food. In the case of gastric bypass, a very common bariatric procedure, restrictive and malabsorptive approaches are combined. Bariatric surgeries are associated with risks for complications, however, including death. Treatment failures can be caused by inability to tolerate surgery-related changes requiring reversals, or post-surgical changes in behavior or anatomy that in effect override the surgically induced restrictions in stomach size. With the advent of minimally invasive surgery, some risks are reduced when procedures are performed using a laparoscope instead of an open procedure (laparotomy).

Major types of bariatric surgeries include gastric banding, gastroplasties, and bypass procedures. Gastric banding positions a band outside the stomach to create a smaller pouch (15 to 30 cc) in the uppermost portion of the stomach in order to restrict food intake. While bands were fixed in circumference at the time of surgery in the past, they are now adjustable through injection of saline into an accessible subcutaneous port. Adjustable gastric bands can be adjusted over time in response to rates of symptoms and weight loss. Bypass procedures reduce caloric intake (and, unfortunately, absorption of essential nutrients) through rerouting food around a portion of the intestinal tract. The bypassed section is generally not removed, which theoretically allows for reversals. Gastric bypass is the most common bariatric surgery in the United States since other forms of bypass (jejunal-ileal; biliopancreatic diversion; biliopancreatic diversion with duodenal switch) have been associated with numerous complications.^39,^ ^40^

Surgeons have developed a variety of surgical approaches to gastric bypass, with some variations even for the most commonly performed type, Roux-en-Y gastric bypass (RYGB). RYGB restricts the size of the stomach to about 30 cc and then bypasses the duodenum to reduce absorption. Gastroplasties mechanically reduce the stomach's size and architecture by creating a stapled anterior gastric pouch with a reduced outlet to the remainder of the stomach. Types of gastroplasty include vertical-banded gastroplasty (VBG), which also uses a band to constrict the stomach and prevent dilatation, gastric partitioning with a band, and horizontal gastroplasty. Gastroplasties are less commonly performed, given their higher degree of recidivism than with gastric bypass, and because less invasive restrictive approaches using gastric banding are now available.

Banding approaches, particularly laparoscopic adjustable gastric banding (LAGB), are particularly appealing for adolescents since they do not involve surgical removal or realignment of the intestine and are therefore more reversible. Banding also retains the entire absorptive area of the stomach and intestines, which lowers risk of malabsorption of essential nutrients. Malabsorptive concerns are particularly important since adolescents are still developing and young females could become pregnant. Finally, banding can routinely be done laparoscopically, which reduces peri-operative complication risks. In the United States, however, FDA approval has not been granted for these devices in those under 18 years.^43^

Potential surgically related risks and the degree of desired weight loss are factors in the choice of bariatric surgical approaches, since these may differ between bariatric procedures.^42^ Banding procedures have been more common outside the United States, but recent utilization data suggest this procedure is becoming relatively more common among obese adults and adolescents undergoing bariatric surgeries in the United States.^44^ Both adjustable gastric banding and gastric bypass are currently considered for severely obese adolescents with serious obesity-related comorbid conditions who have failed medical treatment, but only when performed by highly trained and skilled bariatric surgeons in a program with close nutritional, psychological, and surgical evaluation and followup.^45^