# Appendix H. Quality rating criteria

Design | United States Preventive Services Task Force quality rating criteria^1^ | National Institute for Health and Clinical Excellence methodology checklists^2^
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - The study addresses an appropriate and clearly focused question; - A description of the methodology used is included; - The literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables | - The study addresses an appropriate and clearly focused question; - The cases and controls are taken from comparable populations; - The same exclusion criteria are used for both cases and controls; - What percentage of each group (cases and controls) participated in the study?; - Comparison is made between participants and non-participants to establish their similarities or differences; - Cases are clearly defined and differentiated from controls; - Is it clearly established that controls are non-cases?; - Measures have been taken to prevent knowledge of primary exposure influencing case ascertainment; - Exposure status is measured in a standard, valid and reliable way; - The main potential confounders are identified and taken into account in the design and analysis; - Have confidence intervals been provided?
Randomized controlled trials (RCTs) | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The assignment of subjects to treatment groups is randomized; - An adequate concealment method is used; - Subjects and investigators are kept ‘blind’ about treatment allocation; - The treatment and control groups are similar at the start of the trial; - The only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid and reliable way; - What percentage of the individuals or clusters recruited into each treatment arm of the study dropped out before the study was completed?; - All the subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - Where the study is carried out at more than one site, results are comparable for all sites
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The two groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - The study indicates how many of the people asked to take part did so, in each of the groups being studied; - The likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - What percentage of individuals or clusters recruited into each arm of the study dropped out before the study was completed?; - Comparison is made between full participants and those lost to follow-up, by exposure status; - The outcomes are clearly defined; - The assessment of outcome is made blind to exposure status; - Where blinding was not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - The measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - The main potential confounders are identified and taken into account in the design and analysis; - Have confidence intervals been provided?
Diagnostic accuracy studies | - Screening test relevant, available for primary care, adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate result in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Administration of reliable screening test | - The nature of the test being studied is clearly specified; - The test is compared with an appropriate gold standard; - Where no gold standard exists, a validated reference standard is used as a comparator; - Patients for testing are selected either as a consecutive series or randomly, from a clearly defined study population; - The test and gold standard are measured independently (blind) of each other; - The test and gold standard are applied as close together in time as possible; - Results are reported for all patients that are entered into the study; - A pre-diagnosis is made and reported

## Hierarchy of research design^1^

- I Properly conducted randomized controlled trial (RCT)
- II-1: Well-designed controlled trial without randomization
- II-2: Well-designed cohort or case-control analytic study
- II-3: Multiple time series with or without the intervention; dramatic results from uncontrolled experiments
- III: Opinions of respected authorities, based on clinical experience; descriptive studies or case reports; reports of expert committees

### References for Appendix H

1 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
2 National Institute for Health and Clinical Excellence. (April 2006). ‘The guidelines manual’. London: National Institute for Health and Clinical Excellence. Available from: www.nice.org.uk.