# Appendix G. Study eligibility criteria

1 Populations. The following apply to all Key Questions:
  a Age 2–18. If study substantially overlaps our age range (e.g., 14–65), include article if results for younger participants reported separately. For study of “young adult” or “college-aged”, exclude unless average age is <19 or “college freshmen” is specified.
  b Either (a) entire sample is ≥overweight or obese (85^th^ percentile for age and sex-specific BMI, or who meet previously accepted criteria for overweight based on ideal body weight) or (b) ≥50% of the sample are overweight or obese AND ≥80% of the sample have one of the following risk factors for overweight or obesity-related medical problems: Children of overweight parents; Hispanic, Black, or American Indian/Alaska Native; children with the following medical conditions: diabetes, metabolic syndrome, hypertension, lipid abnormalities, or other cardiovascular-related disorders.
  c Exclude trials in which the sample is limited to youth: (1) with eating disorders, (2) pregnant/ post-partum, (3) overweight/obesity secondary to genetic or medical condition, including Polycystic ovarian syndrome, hypothyroid, Cushings, GH deficiency, insulinoma, hypothalamic disorders (e.g. Froehlich's syndrome), Laurence-Moon-Biedl syndrome, Prader-Willi syndrome, weight gain secondary to medications (e.g., antipsychotics), or (4) other idiosyncratic weight-loss issues.
2 Study Design.
  a All studies for KQ1, KQ2, KQ4, and KQ5 must have an outcomes assessment at 6 months or later post-baseline. No minimum follow-up is required for serious (i.e., requiring urgent medical care) adverse events, KQ3.
  b Behavioral interventions: limit to RCT or CCT with minimal intervention or placebo control, with a minimum of 10 subjects per treatment arm
  c Pharmacological interventions: RCT with placebo pill control, with a minimum of 10 subjects per treatment arm
  d Surgical interventions: RCT, CCT, systematically selected large case-series, large comparative cohort studies.
3 Setting. For Behavioral interventions: all KQ except serious (i.e., requiring urgent medical care) adverse effects (KQ3): limit to countries listed as “high” human development on Human Development Index (over .90): Australia, Austria, Belgium, Canada, Denmark, Finland, France, Germany, Greece, Hong Kong, Iceland, Ireland, Israel, Italy, Japan, Korea, Luxembourg, Netherlands, New Zealand, Norway, Portugal, Singapore, Slovenia, Spain, Sweden, Switzerland, United Kingdom, United States.
4 Intervention.
  a Include behavioral (published ≥1985), pharmacological, complimentary/alternative, surgical, or health care system interventions, singly or combined, designed to promote weight control/loss or weight maintenance, or an important components of weight loss (e.g., physical activity).
  b Exclude trials in which intervention focuses primary prevention, changes in the build environment, jejunal ileal bypass surgery, mazindol.