# Appendix F. Pending Assessment

## References

1 Ahrens W, Bammann K, de HS, et al. Understanding and preventing childhood obesity and related disorders—IDEFICS: a European multilevel epidemiological approach. Nutrition Metabolism & Cardiovascular Diseases. 2006;16(4):302-8.
2 Wen LM, Baur LA, Rissel C, Wardle K, Alperstein G, Simpson JM. Early intervention of multiple home visits to prevent childhood obesity in a disadvantaged population: a home-based randomised controlled trial (Healthy Beginnings Trial). BMC Public Health. 2007;7:76. [pmid: 17490492]. [pmcid: 1877802].
3 Inge TH, Garcia VK, Kirk S, et al. Body composition changes after gastric bypass in morbidly obese adolescents. Obes Res. 2004;12:A53.