# Appendix E. Technical Expert Panel/Peer Reviewers

- Carolyn Summerbell, PhD
- Professor of Human Nutrition
- Assistant Dean (Research), School of Health & Social Care
- University of Teesside

- Laurie Anderson PhD, MPH
- Lead Health Scientist
- Centers for Diseases Control and Prevention
- Guide to Community Preventive Services

- Jean Pierre Chanoine, MD, MPH
- Clinical Professor, Department of Pediatrics, University of British Columbia
- Head of Endocrinology and Diabetes Unit, Children's and Women's Health Centre of BC

- Amy Fine, BSN, MPH
- Health Policy/Program
- Consultant
- The Association of Maternal and Child Health Programs

- Laura L Hayman, PhD, RN, FAAN
- Associate Dean for Research
- Professor of Nursing
- College of Nursing and Health Sciences
- University of Massachuestts-Boston

- William Dietz, MD, MPH
- Division of Nutrition and Physical Activity,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention

- Virginia A. Moyer, M.D., M.P.H. (AAP fellow, Editorial Board AAP Grand Rounds)
- Section Head, Academic General Pediatrics
- Baylor College of Medicine

- Paul Shekelle, MD, MPH
- Director, Southern California Evidence-based Practice Center
- RAND Corporation