# Appendix D. List of excluded studies

## Behavioral interventions

### References Reason for Exclusion

Alexy U, Reinehr T, Sichert-Hellert W, Wollenhaupt A, Kersting M, Andler W. Positive changes of dietary habits after an outpatient training program for overweight children. Nutrition Research. 2006;26(5):202-208. Not a weight loss trial.
Amador M, Ramos LT, Morono M, Hermelo MP. Growth rate reduction during energy restriction in obese adolescents. Exp Clin Endocrinol. 1990;96:73-82. Setting. [pmid: 2279528].
Ambler C, Eliakim A, Brasel JA, Lee WN, Burke G, Cooper DM. Fitness and the effect of exercise training on the dietary intake of healthy adolescents. Int J Obes Relat Metab Disord. 1998;22:354-362. Relevance. [pmid: 9578242].
Arnold, Linda L. The effects of a program of exercise and nutrition on body composition in adolescents and young adults with moderate cognitive disabilities: A descriptive study. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2005;65(11-B):6062. Population.
Ask AS, Hernes S, Aarek I, Johannessen G, Haugen M. Changes in dietary pattern in 15 year old adolescents following a 4 month dietary intervention with school breakfast—a pilot study. Nutrition Journal. 2006;5:33. Did not report relevant outcomes. [pmid: 17150115]. [pmcid: 1713247].
Atlantis E, Barnes EH, Singh MA. Efficacy of exercise for treating overweight in children and adolescents: a systematic review. Int J Obes (Lond). 2006;30:1027-1040. Design. [pmid: 16534526].
Balagopal P, George D, Patton N, et al. Lifestyle-only intervention attenuates the inflammatory state associated with obesity: a randomized controlled study in adolescents. Journal of Pediatrics. 2005;146(3):342-8. Design. [pmid: 15756217].
Balagopal P, George D, Yarandi H, Funanage V, Bayne E. Reversal of obesity-related hypoadiponectinemia by lifestyle intervention: a controlled, randomized study in obese adolescents. Journal of Clinical Endocrinology & Metabolism. 2005;90(11):6192-7. Design. [pmid: 16131584].
Bauer C, Fischer A, Keller U. Effect of sibutramine and of cognitive-behavioural weight loss therapy in obesity and subclinical binge eating disorder. Diabetes, Obesity & Metabolism. 2006;8(3):289-95. Design.
Baumer JH. Obesity and overweight: its prevention, identification, assessment and management. Archives of Disease in Childhood Education & Practice. 2007;92(3):ep92-6. Design.
Becque MD, Katch VL, Rocchini AP, Marks CR, Moorehead C. Coronary risk incidence of obese adolescents: reduction by exercise plus diet intervention. Am J Clin Nutr. 1988;81:605-612. Design.
Beech BM, Klesges RC, Kumanyika SK, et al. Child- and parent-targeted interventions: the Memphis GEMS pilot study. Ethn Dis. 2003;13:S40-S53. Design. [pmid: 12713210].
Berry D, Savoye M, Melkus G, Grey M. An intervention for multiethnic obese parents and overweight children. Applied Nursing Research. 2007;63–71, 2007. Design
Berry D, Sheehan R, Heschel R, Knafl K, Melkus G, Grey M. Family-based interventions for childhood obesity: a review (Structured abstract). SO: Journal of Family Nursing. 2004;10:429-449. Design.
Braet C, Van WM, Van LK. Follow-up results of different treatment programs for obese children. Acta Paediatr. 1997;86:397-402. Design. [pmid: 9174227].
Braet C, Winckel MV. Long-Term Follow-Up of a Cognitive Behavioral Treatment Program for Obese Children. Behavior Therapy. 2000;31:55-74. Design.
Brown R, Sothern M, Suskind R, Udall J, Blecker U. Racial differences in the lipid profiles of obese children and adolescents before and after significant weight loss. Clin Pediatr (Phila). 2000;39:427-431. Design. [pmid: 10914309].
Brownell KD, Kaye FS. A school-based behavior modification, nutrition education, and physical activity program for obese children. Am J Clin Nutr. 1982;35:277-283. Design. [pmid: 7064888].
Butryn ML, Wadden TA. Treatment of overweight in children and adolescents: does dieting increase the risk of eating disorders? (Structured abstract). SO: International Journal of Eating Disorders. 2005;37:285-293. Design.
Campbell KJ, Hesketh KD. Strategies which aim to positively impact on weight, physical activity, diet and sedentary behaviours in children from zero to five years. A systematic review of the literature. Obesity Reviews. 2007;8(4):327-38. Did not report relevant outcomes. [pmid: 17578382].
Chang FT, Hu SH, Wang RS. The effectiveness of dietary instruction in obese school children of southern Taiwan. Kaohsiung J Med Sci. 1998;14:528-535. Setting. [pmid: 9796195].
Chen W, Chen SC, Hsu HS, Lee C. Counseling clinic for pediatric weight reduction: program formulation and follow-up. J Formos Med Assoc. 1997;96:59-62. Setting. [pmid: 9033185].
Clemmens D, Hayman LL. Increasing activity to reduce obesity in adolescent girls: a research review (Provisional record). SO: Journal of Obstetric, Gynecologic and Neonatal Nursing. 2004;33:801-808. Design.
Cliff DP, Wilson A, Okely AD, Mickle KJ, Steele JR. Feasibility of SHARK: A physical activity skill-development program for overweight and obese children. Journal of Science & Medicine in Sport. 2007;10(4):263-7. Design. [pmid: 16911874].
Cole K, Waldrop J, D'Auria J, Garner H. An integrative research review: effective school-based childhood overweight interventions. J Spec Pediatr Nurs. 2006;11:166-177. Design. [pmid: 16774527].
Coleman KJ, Tiller CL, Sanchez J, et al. Prevention of the epidemic increase in child risk of overweight in low-income schools: the El Paso coordinated approach to child health. Archives of Pediatrics & Adolescent Medicine. 2005;159(3):217-24. Relevance. [pmid: 15753263].
Collins CE, Warren J, Neve M, McCoy P, Stokes BJ. Measuring effectiveness of dietetic interventions in child obesity: a systematic review of randomized trials. Arch Pediatr Adolesc Med. 2006;160:906-922. Design. [pmid: 16953014].
Collins CE, Warren JM, Neve M, McCoy P, Stokes B. Systematic review of interventions in the management of overweight and obese children which include a dietary component (Provisional record). SO: International Journal of Evidence Based Healthcare. 2007;5:2-53. Design.
Daley AJ, Copeland RJ, Wright NP, Roalfe A, Wales JK. Exercise therapy as a treatment for psychopathologic conditions in obese and morbidly obese adolescents: a randomized, controlled trial. Pediatrics. 2006;118(5):2126-34. Relevance. [pmid: 17079587].
Daley AJ, Copeland RJ, Wright NP, Wales JK. Protocol for: Sheffield Obesity Trial (SHOT): a randomised controlled trial of exercise therapy and mental health outcomes in obese adolescents [ISRCNT83888112]. BMC Public Health. 2005;5:113. Relevance. [pmid: 16259624]. [pmcid: 1310532].
Danielzik S, Pust S, Landsberg B, Muller MJ. First lessons from the Kiel Obesity Prevention Study (KOPS). International Journal of Obesity. 2005;29(Suppl2):S78-S83. Relevance. [pmid: 16385757].
Davee AM, Blum JE, Devore RL, et al. The vending and a la carte policy intervention in Maine public high schools. Preventing Chronic Disease. 2005;2(Spec no):A14. Design. [pmid: 16263047].
Davis CE, Hunsberger S, Murray DM, et al. Design and statistical analysis for the Pathways study. Am J Clin Nutr. 1999;69:760S-763S. Relevance. [pmid: 10195599].
DeJongh ED, Binkley TL, Specker BL. Fat mass gain is lower in calcium-supplemented than in unsupplemented preschool children with low dietary calcium intakes. American Journal of Clinical Nutrition. 2006;84(5):1123-7. Relevance. [pmid: 17093165]. [pmcid: 1847400].
DeMattia L, Lemont L, Meurer L. Do interventions to limit sedentary behaviours change behaviour and reduce childhood obesity? A critical review of the literature. Obesity Reviews. 2007;8(1):69-81. Design. [pmid: 17212797].
Dennison BA, Russo TJ, Burdick PA, Jenkins PL. An intervention to reduce television viewing by preschool children. Arch Pediatr Adolesc Med. 2004;158:170-176. Relevance. [pmid: 14757609].
Dicken KR, Bell MM. Pedometers as a means to increase walking and achieve weight loss. SO: Journal of the American Board of Family Medicine : JABFM. 2006;19:524-525. Population.
Donnelly JE, Jacobsen DJ, Whatley JE, Hill JO, Swift LL, Cherrington A, Polk B, Tran ZV, Reed G. Nutrition and physical activity program to attenuate obesity and promote physical and metabolic fitness in elementary school children. Obes Res. 1996;4(3):229-243. Prevention trial. [pmid: 8732957].
Dreimane D, Safani D, MacKenzie M, et al. Feasibility of a hospital-based, family-centered intervention to reduce weight gain in overweight children and adolescents. Diabetes Research & Clinical Practice. 2007;75(2):159-68. Design. [pmid: 16837096].
Ebbeling CB, Feldman HA, Osganian SK, Chomitz VR, Ellenbogen SJ, Ludwig DS. Effects of decreasing sugar-sweetened beverage consumption on body weight in adolescents: a randomized, controlled pilot study. Pediatrics. 2006;117(3):673-80. Relevance. [pmid: 16510646].
Ebbeling CB, Garcia-Lago E, Leidig MM, Seger-Shippee LG, Feldman HA, Ludwig DS. Altering portion sizes and eating rate to attenuate gorging during a fast food meal: effects on energy intake. Pediatrics. 2007;119(5):869-75. Relevance. [pmid: 17473086].
Ebbeling CB, Leidig MM, Feldman HA, Lovesky MM, Ludwig DS. Effects of a low-glycemic load vs low-fat diet in obese young adults: a randomized trial. JAMA. 2007;297(19):2092-102. Population. [pmid: 17507345].
Ebbeling CB, Leidig MM, Sinclair KB, Hangen JP, Ludwig DS. A reduced-glycemic load diet in the treatment of adolescent obesity. Archives of Pediatrics & Adolescent Medicine. 2003;157:773-779. Design. [pmid: 12912783].
Economos CD, Hyatt RR, Goldberg JP, et al. A community intervention reduces BMI z-score in children: Shape Up Somerville first year results. Obesity. 2007;15(5):1325-36. Relevance. [pmid: 17495210].
Edwards B. Childhood obesity: a school-based approach to increase nutritional knowledge and activity levels. Nurs Clin North Am. 2005;40:661-6ix. Did not report relevant outcomes. [pmid: 16324939].
Eliakim A, Kaven G, Berger I, Friedland O, Wolach B, Nemet D. The effect of a combined intervention on body mass index and fitness in obese children and adolescents - a clinical experience. Eur J Pediatr. 2002;161:449-454. Did not report relevant outcomes. [pmid: 12172831].
Epstein LH, Kuller LH, Wing RR, Valoski A, McCurley J. The effect of weight control on lipid changes in obese children. Am J Dis Child. 1989;143:454-457. Precedes search period. [pmid: 2929526].
Epstein LH, McCurley J, Wing RR, Valoski A. Five-year follow-up of family-based behavioral treatments for childhood obesity. J Consult Clin Psychol. 1990;58:661-664. Design. [pmid: 2254515].
Epstein LH, McKenzie SJ, Valoski A, Klein KR, Wing RR. Effects of mastery criteria and contingent reinforcement for family-based child weight control 3838. Addictive Behaviors. 1994;19:135-145. Design. [pmid: 8036961].
Epstein LH, Paluch RA, Raynor HA. Sex differences in obese children and siblings in family-based obesity treatment. Obesity Research. 2001;9:746-753. Design. [pmid: 11743058].
Epstein LH, Saelens BE, O'Brien JG. Effects of reinforcing increases in active behavior versus decreases in sedentary behavior for obese children. Int J Behav Med. 1995;2:41-50. Did not report relevant outcomes. [pmid: 16250788].
Epstein LH, Valoski A, McCurley J. Effect of weight loss by obese children on long-term growth. Am J Dis Child. 1993;147:1076-1080. Design. [pmid: 8213679].
Epstein LH, Valoski A, Wing RR, McCurley J. Ten-year outcomes of behavioral family-based treatment for childhood obesity. Health Psychol. 1994;13:373-383. Design. [pmid: 7805631].
Epstein LH, Valosk Ai, Wing RR, McCurley J. Ten-year follow-up of behavioral, family-based treatment for obese children. JAMA. 1990;264(19):2519-2523. Precedes search period. [pmid: 2232019].
Epstein LH, Valoski AM, Kalarchian MA, McCurley J. Do children lose and maintain weight easier than adults: a comparison of child and parent weight changes from six months to ten years. Obes Res. 1995;3:411-417. Did not report relevant outcomes. [pmid: 8521160].
Epstein LH, Wing RR, Koeske R, Andrasik F, Ossip DJ. Child and parent weight loss in family-based behavior modification programs. J Consult Clin Psychol. 1981;49:674-685. Design. [pmid: 7287977].
Epstein LH, Wing RR, Koeske R, Valoski A. Effect of parent weight on weight loss in obese children. J Consult Clin Psychol. 1986;54:400-401. Did not report relevant outcomes. [pmid: 3722572].
Epstein LH, Wing RR, Koeske R, Valoski A. Effects of diet plus exercise on weight change in parents and children. J Consult Clin Psychol. 1984;52:429-437. Precedes search period. [pmid: 6747061].
Epstein LH, Wing RR, Koeske R, Valoski A. Long-term effects of family-based treatment of childhood obesity. J Consult Clin Psychol. 1987;55:91-95. Precedes search period. [pmid: 3106445].
Epstein LH, Valoski A, Koeske R, Wing RR. Family-based behavioral weight control in obese young children. J Am Diet Assoc. 1986;86(4):481-484. Design. [pmid: 3958397].
Epstein LH, Valoski AM, Vara LS, McCurley J, Wisniewski L, Kalarchian MA, Klein KR, Shrager LR. Effects of decreasing sedentary behavior and increasing activity on weight change in obese children 3814. Health Psychology. 1995;14(2):109-115. Design. [pmid: 7789345].
Epstein LHR, Paluch RA, Gordy CC, Dorn J. Decreasing sedentary behaviors in treating pediatric obesity. Arch Pediatr Adolesc Med. 2000;154(3):220-226. Design. [pmid: 10710017].
Epstein LH, Paluch RA, Saelens BE, Ernst MM, Wilfley DE. Changes in eating disorder symptoms with pediatric obesity treatment. J Pediatr. 2001;139(1):58-65. Design. [pmid: 11445795].
Epstein LH, Paluch RA, Kilanowski CK, Raynor HA. The effect of reinforcement or stimulus control to reduce sedentary behavior in the treatment of pediatric obesity. Health Psychol. 2004;23(4):371-380. Design. [pmid: 15264973].
Epstein LH, Paluch RA, Roemmich JN, Beecher MD. Family-based obesity treatment, then and now: Twenty-five years of pediatric obesity treatment. Health Psychol. 2007;26(4):381-391. Design. [pmid: 17605557]. [pmcid: 2387251].
Epstein LH, Wing RR, Valoski A, Penner BC. Stability of food preferences during weight control. A study with 8- to 12-year-old children and their parents. Behav Modif. 1987;11:87-101. Did not report relevant outcomes. [pmid: 3508378].
Figueroa-Colon R, von Almen TK, Franklin FA, Schuftan C, Suskind RM. Comparison of two hypocaloric diets in obese children. Am J Dis Child. 1993;147:160-166. Design. [pmid: 8427238].
Figueroa-Colon R, Franklin FA, Lee JR, von Almen TK, Suskind RM. Feasibility of a clinic-based hypocaloric dietary intervention implemented in a school setting for obese children. Obes Res. 1996;4(5):419-429. Design. [pmid: 8885206].
Flodmark CE, Marcus C, Britton M. Interventions to prevent obesity in children and adolescents: A systematic literature review. International Journal of Obesity. 2006;30(4):579-589. Relevance. [pmid: 16570086].
Flores R. Dance for health: improving fitness in African American and Hispanic adolescents. Public Health Rep. 1995;110(2):189-193. Outcomes < 6 months. [pmid: 7630998]. [pmcid: 1382101].
Foster GD, Wadden TA, Brownell KD. Peer-led program for the treatment and prevention of obesity in the schools. J Consult Clin Psychol. 1985;53:538-540. Design. [pmid: 4031211].
Gately PJ, Cooke CB, Barth JH, Bewick BM, Radley D, Hill AJ. Children's residential weight-loss programs can work: a prospective cohort study of short-term outcomes for overweight and obese children. Pediatrics. 2005;116(1):73-7. Design. [pmid: 15995034].
Gately PJ, King NA, Greatwood HC, et al. Does a High-protein Diet Improve Weight Loss in Overweight and Obese Children?. Obesity. 2007;15(6):1527-34. Design. [pmid: 17557990].
Gibson LJ, Peto J, Warren JM, dos SS I. Lack of evidence on diets for obesity for children: a systematic review. International Journal of Epidemiology. 2006;35(6):1544-52. Design. [pmid: 16984930].
Golan M, Crow S. Targeting parents exclusively in the treatment of childhood obesity: long-term results. Obes Res. 2004;12:357-361. Information provided in another publication. [pmid: 14981230].
Goldfield GS, Mallory R, Parker T, et al. Effects of modifying physical activity and sedentary behavior on psychosocial adjustment in overweight/obese children. Journal of Pediatric Psychology. 2007;32(7):783-93. Design. [pmid: 17449466].
Goldfield GS, Epstein LH, Kilanowski CK, Paluch RA, Kogut-Bossler B. Cost-effectiveness of group and mixed family-based treatment for childhood obesity. Int J Obes Relat Metab Disord. 2001;25(12):1843-1849. Design. [pmid: 11781766].
Gortmaker SL, Peterson K, Wiecha J, et al. Reducing obesity via a school-based interdisciplinary intervention among youth: Planet Health. Arch Pediatr Adolesc Med. 1999;153:409-418. Relevance. [pmid: 10201726].
Graf C, Koch B, Bjarnason-Wehrens B, et al. Who benefits from intervention in, as opposed to screening of, overweight and obese children?. Cardiology in the Young. 2006;16(5):474-80. Did not report relevant outcomes. [pmid: 16984699].
Graves T, Meyers AW, Clark L. An evaluation of parental problem-solving training in the behavioral treatment of childhood obesity. J Consult Clin Psychol. 1988;56:246-250. Design. [pmid: 3372833].
Grey M, Berry D, Davidson M, Galasso P, Gustafson E, Melkus G. Preliminary testing of a program to prevent type 2 diabetes among high-risk youth. J Sch Health. 2004;74(1):10-15. Design. [pmid: 15022370].
Harrell JS, Gansky SA, McMurray RG, Bangdiwala SI, Frauman AC, Bradley CB. School-based interventions improve heart health in children with multiple cardiovascular disease risk factors. Am J Clin Nutr. 1998;102:371-380. Relevance.
Harvey-Berino J, Rourke J. Obesity prevention in preschool native-american children: a pilot study using home visiting. Obes Res. 2003;11:606-611. Relevance. [pmid: 12740449].
Heymsfield SB, van-Mierlo CA, van-der-Knaap HC, Heo M, Frier H I. Weight management using a meal replacement strategy: meta and pooling analysis from six studies (Structured abstract). SO: International Journal of Obesity. 2003;27:537-549. Population.
Hills AP, Parker AW. Obesity management via diet and exercise intervention. Child Care Health Dev. 1988;14:409-416. Design. [pmid: 3228964].
Huang JS, Norman GJ, Zabinski MF, Calfas K, Patrick K. Body image and self-esteem among adolescents undergoing an intervention targeting dietary and physical activity behaviors. Journal of Adolescent Health. 2007;40(3):245-51. Relevance. [pmid: 17321425]. [pmcid: 1819585].
Ildiko V, Zsofia M, Janos M, et al. Activity-related changes of body fat and motor performance in obese seven-year-old boys. Journal of Physiological Anthropology. 2007;26(3):333-7. Setting. [pmid: 17641452].
Intense diet, behavior, and physical activity intervention effective for obese children. J Fam Pract. 2005;54:579. Design
Israel A, Solotar LC, Zimand E. An Investigation of Two Parental Involvement Roles in the Treatment of Obese Children. Int J Eat Disord. 1990;9(5):557-564. Design.
Jago R, Jonker ML, Missaghian M, Baranowski T. Effect of 4 weeks of Pilates on the body composition of young girls. Preventive Medicine. 2006;42(3):177-80. Relevance. [pmid: 16376979].
Jago R, Baranowski T, Baranowski JC, Thompson D, Cullen KW, Watson K, Liu Y. Fit for Life Boy Scout badge: outcome evaluation of a troop and Internet intervention. SO: Preventive medicine. 2006;42(3):181-187. Prevention Trial.
Jelalian E, Mehlenbeck R, Lloyd-Richardson EE, Birmaher V, Wing RR. ‘Adventure therapy’ combined with cognitive-behavioral treatment for overweight adolescents. International Journal of Obesity. 2006;30(1):31-9. Design. [pmid: 16158087].
Jelalian E, Wember YM, Bungeroth H, Birmaher V. Practitioner review: bridging the gap between research and clinical practice in pediatric obesity. Journal of Child Psychology & Psychiatry & Allied Disciplines. 2007;48(2):115-27. Design.
Jiang JX, Xia XL, Greiner T, Lian GL, Rosenqvist U. A two year family based behaviour treatment for obese children. Archives of Disease in Childhood. 2005;90(12):1235-8. Setting. [pmid: 16188958]. [pmcid: 1720215].
Johnston, Craig A, Steele, Ric G. Treatment of Pediatric Overweight: An Examination of Feasibility and Effectiveness in an Applied Clinical Setting. Journal of Pediatric Psychology. 2007;32(1):106-110. Design. [pmid: 16809794].
Jones RA, Okely AD, Collins CE, et al. The HIKCUPS trial: a multi-site randomized controlled trial of a combined physical activity skill-development and dietary modification program in overweight and obese children. BMC Public Health. 2007;7:15. Did not report relevant outcomes. [pmid: 17263896]. [pmcid: 1796868].
Kelly AS, Steinberger J, Olson TP, Dengel DR. In the absence of weight loss, exercise training does not improve adipokines or oxidative stress in overweight children. Metabolism: Clinical & Experimental. 2007;56(7):1005-9. Design. [pmid: 17570265].
Kitzmann, Katherine M, Beech, Bettina M. Family-Based Interventions for Pediatric Obesity: Methodological and Conceptual Challenges From Family Psychology. Journal of Family Psychology. 2006;20(2):175-189. Design. [pmid: 16756393].
Klijn PH, van der Baan-Slootweg OH, van Stel HF. Aerobic exercise in adolescents with obesity: preliminary evaluation of a modular training program and the modified shuttle test. BMC Pediatrics. 2007;7:19. Design. [pmid: 17445257]. [pmcid: 1866229].
Korsten-Reck U, Kromeyer-Hauschild K, Wolfarth B, Dickhuth HH, Berg A. Freiburg Intervention Trial for Obese Children (FITOC): results of a clinical observation study. International Journal of Obesity. 2005;29(4):356-61. Did not report relevant outcomes. [pmid: 15583698].
Lansky D, Vance MA. School-based intervention for adolescent obesity: analysis of treatment, randomly selected control, and self-selected control subjects. J Consult Clin Psychol. 1983;51:147-148. Design. [pmid: 6826860].
Lauer RM, Obarzanek E, Hunsberger SA, Van Horn L, Hartmuller VW, Barton BA, Stevens VJ, Kwiterovich PO Jr, Franklin FA Jr, Kimm SY, Lasser CL, Simons-Morton DG. Efficacy and safety of lowering dietary intake of total fat, saturated fat, and cholesterol in children with elevated LDL cholesterol: the Dietary Intervention Study in Children. Am J Clin Nutr. 2000;72(5 Suppl):1332S-1342S. Not a weight loss trial. [pmid: 11063475].
Levine MD, Ringham RM, Kalarchian MA, Wisniewski L, Marcus MD. Is family-based behavioral weight control appropriate for severe pediatric obesity?. Int J Eat Disord. 2001;30:318-328. Design. [pmid: 11746293].
Lytle LA, Stone EJ, Nichaman MZ, et al. Changes in nutrient intakes of elementary school children following a school-based intervention: results from the CATCH Study. Prev Med. 1996;25:465-477. Relevance. [pmid: 8818069].
Maffeis C, Castellani M. Physical activity: an effective way to control weight in children?. Nutrition Metabolism & Cardiovascular Diseases. 2007;17(5):394-408. Design.
Manios Y, Moschandreas J, Hatzis C, Kafatos A. Evaluation of a health and nutrition education program in primary school children of Crete over a three-year period. Prev Med. 1999;28:149-159. Relevance. [pmid: 10048106].
McLean N, Griffin S, Toney K, Hardeman W. Family involvement in weight control, weight maintenance and weight-loss interventions: a systematic review of randomised trials (Provisional record). SO: International Journal of Obesity. 2003;27:987-1005. Design.
Meyer AA, Kundt G, Lenschow U, Schuff-Werner P, Kienast W. Improvement of early vascular changes and cardiovascular risk factors in obese children after a six-month exercise program. Journal of the American College of Cardiology. 2006;48(9):1865-70. Did not report relevant outcomes. [pmid: 17084264].
Moore, Brie A. and O'Donohue, William T. 225–270. 2005. Design
Moreno LA. Interventions to improve cardiovascular risk factors in obese children. Journal of Pediatric Gastroenterology & Nutrition. 2006;43(4):433-5. Design. [pmid: 17033516].
Mo-suwan L, Pongprapai S, Junjana C, Puetpaiboon A. Effects of a controlled trial of a school-based exercise program on the obesity indexes of preschool children. Am J Clin Nutr. 1998;68:1006-1011. Setting. [pmid: 9808215].
Muller MJ, Asbeck I, Mast M, Langnase K, Grund A. Prevention of obesity—more than an intention. Concept and first results of the Kiel Obesity Prevention Study (KOPS). Int J Obes Relat Metab Disord. 2001;25(Suppl 1):S66-S74. Prevention trial. [pmid: 11466593].
Nemet D, Berger-Shemesh E, Wolach B, Eliakim A. A combined dietary-physical activity intervention affects bone strength in obese children and adolescents. International Journal of Sports Medicine. 2006;27(8):666-71. Design. [pmid: 16874595].
Nova E, Varela P, Lopez-Vidriero I, Toro O, Cena MJ, Casas J, Marcos A. A one-year follow-up study in anorexia nervosa. Dietary pattern and anthropometrical evolution. Eur J Clin Nutr. 2001;55(7):547-554. Population. [pmid: 11464228].
Nuutinen O, Knip M. Long-term weight control in obese children: persistence of treatment outcome and metabolic changes. Int J Obes Relat Metab Disord. 1992;16:279-287. Relevance. [pmid: 1318282].
O'Dea JA, Abraham S. Improving the body image, eating attitudes, and behaviors of young male and female adolescents: a new educational approach that focuses on self-esteem. Int J Eat Disord. 2000;28:43-57. Relevance. [pmid: 10800013].
Owens S, Gutin B, Allison J, et al. Effect of physical training on total and visceral fat in obese children. Med Sci Sports Exerc. 1999;31:143-148. Design. [pmid: 9927022].
Patrick K, Calfas KJ, Norman GJ, et al. Randomized controlled trial of a primary care and home-based intervention for physical activity and nutrition behaviors: PACE+ for adolescents. SO: Archives of pediatrics & adolescent medicine. 2006;160:128-136. Relevance.
Peterson KE, Fox MK. Addressing the epidemic of childhood obesity through school-based interventions: what has been done and where do we go from here?. Journal of Law, Medicine & Ethics. 2007;35(1):113-30. Design.
Poland BD. Learning to ‘walk our talk’: the implications of sociological theory for research methodologies in health promotion. Can J Public Health. 1992;83(Suppl 1):S31-S46. Relevance. [pmid: 1423121].
Ray R, Lim LH, Ling SL. Obesity in preschool children: an intervention programme in primary health care in Singapore. Ann Acad Med Singapore. 1994;23(3):335-341. Design. [pmid: 7944246].
Reinehr T, Kersting M, Alexy U, Andler W. Long-term follow-up of overweight children: after training, after a single consultation session, and without treatment. J Pediatr Gastroenterol Nutr. 2003;37(1):72-74. Quality. [pmid: 12827009].
Reinehr T, de SG, Toschke AM, Andler W. Long-term follow-up of cardiovascular disease risk factors in children after an obesity intervention. American Journal of Clinical Nutrition. 2006;84(3):490-6. Did not report relevant outcomes. [pmid: 16960161].
Reinehr T, de SG, Wabitsch M. Changes of cardiovascular risk factors in obese children effects of inpatient and outpatient intervention. Journal of Pediatric Gastroenterology & Nutrition. 2006;43(4):506-11. Information provided in another publication. [pmid: 17033527].
Resnicow K, Davis R, Rollnick S. Motivational interviewing for pediatric obesity: Conceptual issues and evidence review. Journal of the American Dietetic Association. 2006;106(12):2024-33. Design. [pmid: 17126634].
Resnicow K, Yaroch AL, Davis A, et al. GO GIRLS!: results from a nutrition and physical activity program for low-income, overweight African American adolescent females. Health Educ Behav. 2000;27:616-631. Design. [pmid: 11009130].
Reybrouck T, Vinckx J, Van den BG, Vanderschueren-Lodeweyckx M. Exercise therapy and hypocaloric diet in the treatment of obese children and adolescents. Acta Paediatr Scand. 1990;79:84-89. Did not report relevant outcomes. [pmid: 2316366].
Robbins LB, Gretebeck KA, Kazanis AS, Pender NJ. Girls on the move program to increase physical activity participation. Nursing Research. 2006;55(3):206-16. Jun. Design. [pmid: 16708045].
Robinson TN. Reducing children's television viewing to prevent obesity: a randomized controlled trial. JAMA. 1999;282:1561-1567. Relevance. [pmid: 10546696].
Rocchini AP, Katch V, Anderson J, et al. Blood pressure in obese adolescents: effect of weight loss. Am J Clin Nutr. 1988;82:16-23. Design.
Rocchini AP, Katch V, Schork A, Kelch RP. Insulin and blood pressure during weight loss in obese adolescents. Hypertension. 1987;10:267-273. Design. [pmid: 3305355].
Rodearmel SJ, Wyatt HR, Barry MJ, et al. A family-based approach to preventing excessive weight gain. Obesity. 2006;14(8):1392-401. Design. [pmid: 16988082].
Rolland-Cachera MF, Thibault H, Souberbielle JC, Soulie D, Carbonel P, Deheeger M, Roinsol D, Longueville E, Bellisle F, Serog P. Massive obesity in adolescents: dietary interventions and behaviours associated with weight regain at 2 y follow-up. Int J Obes Relat Metab Disord. 2004;28(4):514-519. Design. [pmid: 14968129].
Rosenbaum M, Nonas C, Weil R, et al. School-based intervention acutely improves insulin sensitivity and decreases inflammatory markers and body fatness in junior high school students. Journal of Clinical Endocrinology & Metabolism. 2007;92(2):504-8. Design. [pmid: 17090635].
Salmon J, Booth ML, Phongsavan P, Murphy N, Timperio A. Promoting Physical Activity Participation among Children and Adolescents. Epidemiologic Reviews. 2007;29:144-59. Design. [pmid: 17556765].
Sasaki J, Shindo M, Tanaka H, Ando M, Arakawa K. A long-term aerobic exercise program decreases the obesity index and increases the high density lipoprotein cholesterol concentration in obese children. Int J Obes. 1987;11:339-345. Design. [pmid: 3667067].
Schwartz RP, Hamre R, Dietz WH, et al. Office-based motivational interviewing to prevent childhood obesity: a feasibility study. Archives of Pediatrics & Adolescent Medicine. 2007;161(5):495-501. Did not meet quality criteria. [pmid: 17485627].
Schwingshandl J, Sudi K, Eibl B, Wallner S, Borkenstein M. Effect of an individualised training programme during weight reduction on body composition: a randomised trial. Arch Dis Child. 1999;81:426-428. Design. [pmid: 10519718]. [pmcid: 1718135].
Shaibi GQ, Cruz ML, Ball GD, et al. Effects of resistance training on insulin sensitivity in overweight Latino adolescent males. Medicine & Science in Sports & Exercise. 2006;38(7):1208-15. Design. [pmid: 16826016].
Sharma M. School-based interventions for childhood and adolescent obesity. Obesity Reviews. 2006;7(3):261-9. Design. [pmid: 16866974].
Sherry B. Food behaviors and other strategies to prevent and treat pediatric overweight. International Journal of Obesity. 2005;29(Suppl 2):S116-26. Design. [pmid: 16385763].
Singh AS, Paw MJ, Brug J, van MW. Short-term effects of school-based weight gain prevention among adolescents. Archives of Pediatrics & Adolescent Medicine. 2007;161(6):565-71. Relevance. [pmid: 17548761].
Snethen JA, Broome ME, Cashin SE. Effective weight loss for overweight children: a meta-analysis of intervention studies. Journal of Pediatric Nursing. 2006;21(1):45-56. Design. [pmid: 16428013].
Sondike SB, Copperman N, Jacobson MS. Effects of a low-carbohydrate diet on weight loss and cardiovascular risk factor in overweight adolescents. J Pediatr. 2003;142:253-258. Design. [pmid: 12640371].
Sothern MS, Despinasse B, Brown R, Suskind RM, Udall JN Jr, Blecker U. Lipid profiles of obese children and adolescents before and after significant weight loss: differences according to sex. South Med J. 2000;93:278-282. Design. [pmid: 10728514].
Sothern MS, Hunter S, Suskind RM, Brown R, Udall JN Jr, Blecker U. Motivating the obese child to move: the role of structured exercise in pediatric weight management. South Med J. 1999;92:577-584. Design. [pmid: 10372851].
Sothern MS, Loftin JM, Udall JN, et al. Safety, feasibility, and efficacy of a resistance training program in preadolescent obese children. Am J Med Sci. 2000;319:370-375. Design. [pmid: 10875292].
Sothern MS, Schumacher H, von Almen TK, Carlisle LK, Udall JN. Committed to kids: an integrated, 4-level team approach to weight management in adolescents. J Am Diet Assoc. 2002;102:S81-S85. Design. [pmid: 11905462].
Sothern, Udall JN Jr, Suskind RM, Vargas A, Blecker U. Weight loss and growth velocity in obese children after very low calorie diet, exercise, and behavior modification. Acta Paediatr. 2000;89:1036-1043. Design. [pmid: 11071081].
Southard DR, Southard BH. Promoting physical activity in children with MetaKenkoh. Clinical & Investigative Medicine - Medecine Clinique et Experimentale. 2006;29(5):293-7. Design. [pmid: 17144438].
Spieth LE, Harnish JD, Lenders CM, et al. A low-glycemic index diet in the treatment of pediatric obesity. Arch Pediatr Adolesc Med. 2000;154:947-951. Design. [pmid: 10980801].
Sung RY, Yu CW, Chang SK, Mo SW, Woo KS, Lam CW. Effects of dietary intervention and strength training on blood lipid level in obese children. Arch Dis Child. 2002;86:407-410. Design. [pmid: 12023168]. [pmcid: 1763008].
Tanas R, Marcolongo R, Pedretti S, Gilli G. A family-based education program for obesity: a three-year study. BMC Pediatr. 2007;7(1):33. Design. [pmid: 17953755]. [pmcid: 2194673].
Temple JL, Wrotniak BH, Paluch RA, Roemmich JN, Epstein LH. Relationship between sex of parent and child on weight loss and maintenance in a family-based obesity treatment program. International Journal of Obesity. 2006;30(8):1260-4. Design. [pmid: 16491111].
Vido L, Facchin P, Antonello I, Gobber D, Rigon F. Childhood obesity treatment: double blinded trial on dietary fibres (glucomannan) versus placebo. Padiatr Padol. 1993;28:133-136. Design. [pmid: 8247594].
Viner R, Nicholls D. Managing obesity in secondary care: a personal practice. Arch Dis Child. 2005;90:385-390. Design. [pmid: 15781930]. [pmcid: 1720364].
Viski-Stalec N, Stalec J, Kati R, Podvorac D, Katovi D. The impact of dance-aerobics training on the morpho-motor status in female high-schoolers. Collegium Antropologicum. 2007;31(1):259-66. Setting. [pmid: 17598411].
Warschburger P, Fromme C, Petermann F, Wojtalla N, Oepen J. Conceptualisation and evaluation of a cognitive-behavioural training programme for children and adolescents with obesity. Int J Obes Relat Metab Disord. 2001;25(Suppl 1):S93-S95. Design. [pmid: 11466598].
Williams CL, Strobino BA, Bollella M, Brotanek J. Cardiovascular risk reduction in preschool children: the “Healthy Start” project. J Am Coll Nutr. 2004;23:117-123. Relevance. [pmid: 15047677].
Williams CL, Strobino BA, Brotanek J. Weight control among obese adolescents: A pilot study. International Journal of Food Sciences & Nutrition. 2007;58(3):217-30. Design. [pmid: 17514539].
Young KM, Northern JJ, Lister KM, Drummond JA, O'Brien WH. A meta-analysis of family-behavioral weight-loss treatments for children. Clinical Psychology Review. 2007;27(2):240-9. Design. [pmid: 17070638].
Young-Hyman D, Schlundt DG, Herman L, De LF, Counts D. Evaluation of the insulin resistance syndrome in 5- to 10-year-old overweight/obese African-American children. Diabetes Care. 2001;24:1359-1364. Relevance. [pmid: 11473070].
Zemel MB, Richards J, Mathis S, Milstead A, Gebhardt L, Silva E. Dairy augmentation of total and central fat loss in obese subjects.[see comment]. International Journal of Obesity. 2005;29(4):391-7. Relevance. [pmid: 15672113].

## Pharmacological interventions

### References Reason for Exclusion

Appolinario JC, Bacaltchuk J, Sichieri R, et al. A randomized, double-blind, placebo-controlled study of sibutramine in the treatment of binge-eating disorder. Archives of General Psychiatry. 2003;60(11):1109-16. Population. [pmid: 14609886].
Bauer C, Fischer A, Keller U. Effect of sibutramine and of cognitive-behavioural weight loss therapy in obesity and subclinical binge eating disorder. Diabetes, Obesity & Metabolism. 2006;8(3):289-95. Design.
Birkenfeld AL, Schroeder C, Pischon T, et al. Paradoxical effect of sibutramine on autonomic cardiovascular regulation in obese hypertensive patients—sibutramine and blood pressure. Clinical Autonomic Research. 2005;15(3):200-6. Population. [pmid: 15944869].
Cuellar GE, Ruiz AM, Monsalve MC, Berber A. Six-month treatment of obesity with sibutramine 15 mg; a double-blind, placebo-controlled monocenter clinical trial in a Hispanic population. Obes Res. 2000;8:71-82. Population. [pmid: 10678261].
Curran MP, Scott LJ. Orlistat: a review of its use in the management of patients with obesity. Drugs. 2004;64(24):2845-64. Design. [pmid: 15563254].
Danielsson P, Janson A, Norgren S, Marcus C. Impact sibutramine therapy in children with hypothalamic obesity or obesity with aggravating syndromes. J Clin Endocrinol Metab. 2007. Population
Dastjerdi M, Siavash, Kazemi F, Najafian A, Mohammady M, Aminorroaya A, Amini M, Amini M. An open-label pilot study of the combination therapy of metformin and fluoxetine for weight reduction. International Journal of Obesity. 2007;31(4):713-717. Population. [pmid: 16969361].
Erdmann J, Lippl F, Klose G, Schusdziarra V. Cholesterol lowering effect of dietary weight loss and orlistat treatment—efficacy and limitations. Alimentary Pharmacology & Therapeutics. 2004;1173–1179. Population
Fanghanel G, Cortinas L, Sanchez-Reyes L, Berber A. A clinical trial of the use of sibutramine for the treatment of patients suffering essential obesity. Int J Obes Relat Metab Disord. 2000;24:144-150. Population. [pmid: 10702763].
Freemark M. Pharmacotherapy of childhood obesity: an evidence-based, conceptual approach. Diabetes Care. 2007;30:395-402. Design. [pmid: 17259519].
Gilliam FG, Veloso F, Bomhof MA, et al. A dose-comparison trial of topiramate as monotherapy in recently diagnosed partial epilepsy. Neurology. 2003;60(2):196-202. Relevance. [pmid: 12552030].
Greenway FL, De JL, Blanchard D, Frisard M, Smith SR. Effect of a dietary herbal supplement containing caffeine and ephedra on weight, metabolic rate, and body composition. Obesity Research. 2004;12(7):1152-7. Population. [pmid: 15292480].
Hamilton J, Cummings E, Zdravkovic V, Finegood D, Daneman D. Metformin as an adjunct therapy in adolescents with type 1 diabetes and insulin resistance: a randomized controlled trial. Diabetes Care. 2003;26(1):138-43. Population. [pmid: 12502670].
Henness S, Perry CM. Orlistat: a review of its use in the management of obesity. Drugs. 2006;66(12):1625-56. Design. [pmid: 16956313].
Ioannides-Demos LL, Proietto J, Tonkin AM, McNeil JJ. Safety of drug therapies used for weight loss and treatment of obesity. Drug Safety. 2006;29(4):277-302. Design. [pmid: 16569079].
James WP, Astrup A, Finer N, et al. Effect of sibutramine on weight maintenance after weight loss: a randomised trial. STORM Study Group. Sibutramine Trial of Obesity Reduction and Maintenance. Lancet. 2000;356:2119-2125. Population. [pmid: 11191537].
Jordan J, Scholze J, Matiba B, Wirth A, Hauner H, Sharma AM. Influence of Sibutramine on blood pressure: evidence from placebo-controlled trials. International Journal of Obesity. 2005;29(5):509-16. Population. [pmid: 15685250].
Junior AC, Savassi-Rocha PR, Coelho LG, et al. Botulinum A toxin injected into the gastric wall for the treatment of class III obesity: a pilot study. Obesity Surgery. 2006;16(3):335-43. Population. [pmid: 16545166].
Kay JP, Alemzadeh R, Langley G, D'Angelo L, Smith P, Holshouser S. Beneficial effects of metformin in normoglycemic morbidly obese adolescents. Metabolism. 2001;50:1457-1461. Did not meet quality criteria. [pmid: 11735093].
Larsen TM, Toubro S, Gudmundsen O, Astrup A. Conjugated linoleic acid supplementation for 1 y does not prevent weight or body fat regain. American Journal of Clinical Nutrition. 2006;83(3):606-12. Population. [pmid: 16522907].
Li Z, Maglione M, Tu W, et al. Meta-analysis: pharmacologic treatment of obesity. Ann Intern Med. 2005;142:532-546. Population. [pmid: 15809465].
McDuffie JR, Calis KA, Booth SL, Uwaifo GI, Yanovski JA. Effects of orlistat on fat-soluble vitamins in obese adolescents. Pharmacotherapy. 2002;22:814-822. Design. [pmid: 12126214].
McDuffie JR, Calis KA, Uwaifo GI, et al. Efficacy of orlistat as an adjunct to behavioral treatment in overweight African American and Caucasian adolescents with obesity-related co-morbid conditions. Journal of Pediatric Endocrinology. 2004;17(3):307-19. Design.
McDuffie JR, Calis KA, Uwaifo GI, et al. Three-month tolerability of orlistat in adolescents with obesity-related comorbid conditions. Obes Res. 2002;10:642-650. Design. [pmid: 12105286].
McElroy SL, Shapira NA, Arnold LM, et al. Topiramate in the long-term treatment of binge-eating disorder associated with obesity. Journal of Clinical Psychiatry. 2004;65(11):1463-9. Population. [pmid: 15554757].
Norgren S, Danielsson P, Jurold R, Lotborn M, Marcus C. Orlistat treatment in obese prepubertal children: a pilot study. Acta Paediatrica. 2003;92(6):666-70. Design. [pmid: 12856974].
Ozkan B, Bereket A, Turan S, Keskin S. Addition of orlistat to conventional treatment in adolescents with severe obesity. Eur J Pediatr. 2004;163(12):738-741. Design. [pmid: 15378354].
Reith D, Burke C, Appleton DB, Wallace G, Pelekanos J. Tolerability of topiramate in children and adolescents.[see comment]. Journal of Paediatrics & Child Health. 2003;39(6):416-9. Relevance. [pmid: 12919493].
Reisler G, Tauber T, Afriat R, Bortnik O, Goldman M. Sibutramine as an adjuvant therapy in adolescents suffering from morbid obesity. Isr Med Assoc J. 2006;8(1):30-32. Design. [pmid: 16450748].
Scheen AJ, Finer N, Hollander P, Jensen MD, Van Gaal LF. RIO-Diabetes Study Group. Efficacy and tolerability of rimonabant in overweight or obese patients with type 2 diabetes: a randomised controlled study. Lancet. 2006;368(9548):1660-72. Population. [pmid: 17098084].
Summaries for patients. Effects of drug treatment for obesity in adolescence.[original report in Ann Intern Med. 2006 Jul 18;145(2):81–90; PMID: 16847290]. Annals of Internal Medicine 145 (2):I16. 2006. Design
Zhi J, Moore R, Kanitra L. The effect of short-term (21-day) orlistat treatment on the physiologic balance of six selected macrominerals and microminerals in obese adolescents. Journal of the American College of Nutrition. 2003;22(5):357-62. Not relevant outcomes. [pmid: 14559927].
Zilberstein B, Pajecki D, Garcia de Brito AC, Gallafrio ST, Eshkenazy R, Andrade CG. Topiramate after adjustable gastric banding in patients with binge eating and difficulty losing weight. Obesity Surgery. 2004;14(6):802-5. Jul. Population. [pmid: 15318986].

## Surgical interventions

### References Reason for Exclusion

Abu-Abeid S, Szold A. Results and complications of laparoscopic adjustable gastric banding: an early and intermediate experience. Obes Surg. 1999;9:188-190. Population. [pmid: 10340776].
Alden JF. Gastric and jejunoileal bypass. A comparison in the treatment of morbid obesity. Arch Surg. 1977;112:799-806. Population. [pmid: 880023].
Alper D, Ramadan E, Vishne T, et al. Silastic ring vertical gastroplasty- long-term results and complications. Obes Surg. 2000;10:250-254. Population. [pmid: 10929157].
Angrisani L, Lorenzo M, Borrelli V, Giuffre M, Fonderico C, Capece G. Is bariatric surgery necessary after intragastric balloon treatment?. Obesity Surgery. 2006;16(9):1135-7. Population. [pmid: 16989695].
Baltasar A, Bou R, Arlandis F, et al. Vertical banded gastroplasty at more than 5 years. Obes Surg. 1998;8:29-34. Population. [pmid: 9562483].
Benotti P, Wood GC, Still C, Petrick A, Strodel W. Obesity disease burden and surgical risk. Surgery for Obesity & Related Diseases. 2006;2(6):600-6. Dec. Population. [pmid: 16996319].
Biertho L, Steffen R, Branson R, et al. Management of failed adjustable gastric banding?. Surgery. 2005;137(1):33-41. Population. [pmid: 15614279].
Boschi S, Fogli L, Berta RD, et al. Avoiding complications after laparoscopic esophago-gastric banding: experience with 400 consecutive patients. Obesity Surgery. 2006;16(9):1166-70. Population. [pmid: 16989700].
Bowne WB, Julliard K, Castro AE, Shah P, Morgenthal CB, Ferzli GS. Laparoscopic gastric bypass is superior to adjustable gastric band in super morbidly obese patients: A prospective, comparative analysis. Archives of Surgery. 2006;141(7):683-9. Population. [pmid: 16847241].
Carbajo M, Garcia-Caballero M, Toledano M, Osorio D, Garcia-Lanza C, Carmona JA. One-anastomosis gastric bypass by laparoscopy: results of the first 209 patients. Obesity Surgery. 2005;15(3):398-404. Population. [pmid: 15826476].
Carmody BJ, Sugerman HJ, Kellum JM et al. Pulmonary embolism complicating bariatric surgery: detailed analysis of a single institution's 24-year experience. Journal of the American College of Surgeons. 2006;831–7. Population
Csendes A, Burdiles P, Burgos AM, Maluenda F, Diaz JC. Conservative management of anastomotic leaks after 557 open gastric bypasses. Obesity Surgery. 2005;15(9):1252-6. Population. [pmid: 16259881].
Dallal RM, Bailey LA. Omental infarction: a cause of acute abdominal pain after antecolic gastric bypass. Surgery for Obesity & Related Diseases. 2006;2(4):451-4. Aug. Population. [pmid: 16925379].
Dargent J. Laparoscopic adjustable gastric banding: lessons from the first 500 patients in a single institution. Obes Surg. 1999;9:446-452. Population. [pmid: 10605901].
de ZM, Lancaster KL, Mitchell JE, et al. Health-related quality of life in morbidly obese patients: effect of gastric bypass surgery. Obes Surg. 2002;12:773-780. Population. [pmid: 12568181].
Field RJ Jr, Field RJ III, Park SY. Vertical banded gastroplasty: is obesity worth it?. J Miss State Med Assoc. 1992;33:423-432. Population. [pmid: 1474572].
Fielding GA, Duncombe JE. Clinical and radiological follow-up of laparoscopic adjustable gastric bands, 1998 and 2000: a comparison of two techniques. Obesity Surgery. 2005;15(5):634-40. Population. [pmid: 15946453].
Fobi MA, Lee H, Felahy B, Che-Senge K, Fields CB, Sanguinette MC. Fifty consecutive patients with the GaBP ring system used in the banded gastric bypass operation for obesity with follow up of at least 1 year. Surgery for Obesity & Related Diseases. 2005;1(6):569-72. Dec. Population. [pmid: 16925294].
Forestieri P, Meucci L, De Luca M, et al. Two years of practice in adjustable silicone gastric banding (LAP-BAND): evaluation of variations in body mass index, percentage ideal body weight and percentage excess body fat. 1. Obes Surg. 1998;8:49-52. Population. [pmid: 9562487].
Freeman JB, Kotlarewsky M, Phoenix C. Weight loss after extended gastric bypass. Obes Surg. 1997;7:337-344. Population. [pmid: 9730521].
Goulding ST, Hovell BC. Anaesthetic experience of vertical banded gastroplasty. Br J Anaesth. 1995;75:301-306. Population. [pmid: 7547048].
Greenstein RJ, Rabner JG. Is Adolescent Gastric-Restrictive Antiobesity Surgery Warranted?. Obes Surg. 1995;5:138-144. Only self-reported outcomes. [pmid: 10733801].
Haynes B. Creation of a bariatric surgery program for adolescents at a major teaching hospital. Pediatric Nursing 31(1):21–2, 59. 2005;-Feb. Design
Helmrath MA, Brandt ML, Inge TH. Adolescent obesity and bariatric surgery. Surg Clin North Am. 2006;86:441-454. Design. [pmid: 16580933].
Herve J, Wahlen CH, Schaeken A, et al. What becomes of patients one year after the intragastric balloon has been removed?. Obesity Surgery. 2005;15(6):864-70. Jul. Population. [pmid: 15978160].
Higa KD, Boone KB, Ho T, Davies OG. Laparoscopic Roux-en-Y gastric bypass for morbid obesity: technique and preliminary results of our first 400 patients. Arch Surg. 2000;135:1029-1033. Population. [pmid: 10982506].
Higa KD, Boone KB, Ho T. Complications of the laparoscopic Roux-en-Y gastric bypass: 1,040 patients—what have we learned?. Obes Surg. 2000;10:509-513. Population. [pmid: 11175957].
Inge TH, Xanthakos SA, Zeller MH. Bariatric surgery for pediatric extreme obesity: now or later?. International Journal of Obesity. 2007;31(1):1-14. Design. [pmid: 17173060].
Inge TH, Zeller MH, Lawson ML, Daniels SR. A critical appraisal of evidence supporting a bariatric surgical approach to weight management for adolescents?. Journal of Pediatrics. 2005;147(1):10-9. Design. [pmid: 16027686].
Jones DB. Laparoscopic surgery for obesity. Asian Journal of Surgery. 2006;29(4):217-22. Design. [pmid: 17098651].
Kalfarentzos F, Dimakopoulos A, Kehagias I, Loukidi A, Mead N. Vertical banded gastroplasty versus standard or distal Roux-en-Y gastric bypass based on specific selection criteria in the morbidly obese: preliminary results. Obes Surg. 1999;9:433-442. Population. [pmid: 10605899].
Keidar A, Carmon E, Szold A, bu-Abeid S. Port complications following laparoscopic adjustable gastric banding for morbid obesity.[see comment]. Obesity Surgery. 2005;15(3):361-5. Population. [pmid: 15826470].
Kinzl JF, Schrattenecker M, Traweger C, Mattesich M, Fiala M, Biebl W. Psychosocial predictors of weight loss after bariatric surgery. Obesity Surgery. 2006;16(12):1609-14. Population. [pmid: 17217637].
Lee WJ, Wang W, Wei PL, Huang MT. Weight loss and improvement of obesity-related illness following laparoscopic adjustable gastric banding procedure for morbidly obese patients in Taiwan. J Formos Med Assoc. 2006;105:887-94. Population. [pmid: 17098690].
Leifsson BG, Gislason HG. Laparoscopic Roux-en-Y gastric bypass with 2-metre long biliopancreatic limb for morbid obesity: technique and experience with the first 150 patients. Obesity Surgery. 2005;15(1):35-42. Population. [pmid: 15760497].
Madan AK, Orth WS, Ternovits CA, Tichansky DS. Preoperative carbohydrate “addiction” does not predict weight loss after laparoscopic gastric bypass. Obesity Surgery. 2006;16(7):879-82. Population. [pmid: 16839486].
Madan AK, Speck KE, Ternovits CA, Tichansky DS. Outcome of a clinical pathway for discharge within 48 hours after laparoscopic gastric bypass. American Journal of Surgery. 2006;399–402. Population
Maggard MA, Shugarman LR, Suttorp M, et al. Meta-analysis: surgical treatment of obesity. Ann Intern Med. 2005;142:547-559. Population. [pmid: 15809466].
Marinari GM, Papadia FS, Briatore L, Adami G, Scopinaro N. Type 2 diabetes and weight loss following biliopancreatic diversion for obesity. Obesity Surgery. 2006;16(11):1440-4. Population. [pmid: 17132408].
McCarty TM, Arnold DT, Lamont JP, Fisher TL, Kuhn JA. Optimizing outcomes in bariatric surgery: outpatient laparoscopic gastric bypass. Annals of Surgery. discussion 498 –501. 2005;242(4):494-8. Population. [pmid: 16192809]. [pmcid: 1402348].
Melissas J, Mouzas J, Filis D, et al. The intragastric balloon - smoothing the path to bariatric surgery. Obesity Surgery. 2006;16(7):897-902. Population. [pmid: 16839490].
Miller K, Hell E. Laparoscopic adjustable gastric banding: a prospective 4-year follow-up study. Obes Surg. 1999;9:183-187. Population. [pmid: 10340775].
Moon HS, Kim WW, Oh JH. Results of laparoscopic sleeve gastrectomy (LSG) at 1 year in morbidly obese Korean patients. Obesity Surgery. 2005;15(10):1469-75. Dec. Population. [pmid: 16354529].
Nocca D, Frering V, Gallix B et al. Migration of adjustable gastric banding from a cohort study of 4236 patients. Surgical Endoscopy. 2005;947–950. Population
O'Brien PE, Brown WA, Smith A, McMurrick PJ, Stephens M. Prospective study of a laparoscopically placed, adjustable gastric band in the treatment of morbid obesity. Br J Surg. 1999;86:113-118. Population. [pmid: 10027373].
O'Brien PE, Dixon JB, Brown W, et al. The laparoscopic adjustable gastric band (Lap-Band): a prospective study of medium-term effects on weight, health and quality of life. Obes Surg. 2002;12:652-660. Population. [pmid: 12448387].
Oh CH, Kim HJ, Oh S. Weight loss following transected gastric bypass with proximal Roux-en-Y. Obes Surg. 1997;7:142-147. Population. [pmid: 9730542].
Organ CH Jr, Kessler E, Lane M. Long-term results of jejunoileal bypass in the young. Am Surg. 1984;50:589-593. Study not one of the specified interventions. [pmid: 6497180].
Parikh M, Duncombe J, Fielding GA. Laparoscopic adjustable gastric banding for patients with body mass index of <or=35 kg/m2. Surgery for Obesity & Related Diseases. 2006;2(5):518-22. Oct. Population. [pmid: 17015204].
Parikh MS, Laker S, Weiner M, Hajiseyedjavadi O, Ren CJ. Objective comparison of complications resulting from laparoscopic bariatric procedures. Journal of the American College of Surgeons. 2006;252–61, 2006. Population
Paroz A, Calmes JM, Giusti V, Suter M. Internal hernia after laparoscopic Roux-en-Y gastric bypass for morbid obesity: a continuous challenge in bariatric surgery. Obesity Surgery. 2006;16(11):1482-7. Population. [pmid: 17132415].
Prachand VN, Davee RT, Alverdy JC. Duodenal switch provides superior weight loss in the super-obese (BMI > or =50 kg/m2) compared with gastric bypass. Annals of Surgery. 2006;244(4):611-9. Population. [pmid: 16998370]. [pmcid: 1856567].
Randolph JG, Weintraub WH, Rigg A. Jejunoileal bypass for morbid obesity in adolescents. J Pediatr Surg. 1974;9:341-345. Study not one of the specified interventions. [pmid: 4843988].
Rigg CA. Proceedings: Jejunoileal bypass by morbidly obese adolescent. Acta Paediatr Scand Suppl. 1975;62–64. Study not one of the specified interventions
Rutledge R, Walsh TR. Continued excellent results with the mini-gastric bypass: six-year study in 2,410 patients. Obesity Surgery. 2005;15(9):1304-8. Population. [pmid: 16259892].
Salinas A, Santiago E, Yeguez J, Antor M, Salinas H. Silastic ring vertical gastric bypass: evolution of an open surgical technique, and review of 1,588 cases. Obesity Surgery. 2005;15(10):1403-7. Dec. Population. [pmid: 16354519].
Schauer PR, Ikramuddin S, Gourash W, Ramanathan R, Luketich J. Outcomes after laparoscopic Roux-en-Y gastric bypass for morbid obesity. Ann Surg. 2000;232:515-529. Population. [pmid: 10998650]. [pmcid: 1421184].
Scopinaro N, Gianetta E, Adami GF, et al. Biliopancreatic diversion for obesity at eighteen years. Surgery. 1996;119:261-268. Population. [pmid: 8619180].
Shargorodsky M, Fleed A, Boaz M, Gavish D, Zimlichman R. The effect of a rapid weight loss induced by laparoscopic adjustable gastric banding on arterial stiffness, metabolic and inflammatory parameters in patients with morbid obesity. International Journal of Obesity. 2006;30(11):1632-8. Population. [pmid: 16552402].
Silber T, Randolph J, Robbins S. Long-term morbidity and mortality in morbidly obese adolescents after jejunoileal bypass. J Pediatr. 1986;108:318-322. Study not one of the specified interventions. [pmid: 3944722].
Suter M, Paroz A, Calmes JM, Giusti V. European experience with laparoscopic Roux-en-Y gastric bypass in 466 obese patients. British Journal of Surgery. 2006;93(6):726-32. Population. [pmid: 16671063].
Szold A, bu-Abeid S. Laparoscopic adjustable silicone gastric banding for morbid obesity: results and complications in 715 patients. Surg Endosc. 2002;16:230-233. Population. [pmid: 11967669].
Szomstein S, Whipple OC, Zundel N, Cal P, Rosenthal R. Laparoscopic Roux-en-Y gastric bypass with linear cutter technique: comparison of four-row versus six-row cartridge in creation of anastomosis. Surgery for Obesity & Related Diseases. 2006;2(4):431-4. Aug. Population. [pmid: 16925374].
Thomusch O, Keck T, Dobschutz EV, Wagner C, Ruckauer KD, Hopt UT. Risk factors for the intermediate outcome of morbid obesity after laparoscopically placed adjustable gastric banding. American Journal of Surgery. 2005;189(2):214-8. Population. [pmid: 15720994].
Wang HH, Lee WJ, Liew PL, et al. The influence of Helicobacter pylori infection and corpus gastritis on the postoperative outcomes of laparoscopic vertical banded gastroplasty. Obesity Surgery. 2006;16(3):297-307. Population. [pmid: 16545161].
Weller WE, Rosati C, Hannan EL. Relationship between surgeon and hospital volume and readmission after bariatric operation. Journal of the American College of Surgeons. 2007;383–91. Population
White JJ, Cheek D, Haller JA Jr. Small bowel bypass is applicable for adolescents with morbid obesity. Am Surg. 1974;40:704-708. Design. [pmid: 4429281].
White S, Brooks E, Jurikova L, Stubbs RS. Long-term outcomes after gastric bypass. Obesity Surgery. 2005;15(2):155-63. Population. [pmid: 15802056].
Yale CE, Weiler SJ. Weight control after vertical banded gastroplasty for morbid obesity. Am J Surg. 1991;162:13-18. Population. [pmid: 2063963].
Zappa MA, Micheletto G, Lattuada E, et al. Prevention of pouch dilatation after laparoscopic adjustable gastric banding. Obesity Surgery. 2006;16(2):132-6. Population. [pmid: 16469212].
Zehetner J, Holzinger F, Triaca H, Klaiber C. A 6-year experience with the Swedish adjustable gastric band Prospective long-term audit of laparoscopic gastric banding. Surgical Endoscopy. 2005;21–28. Population
Zilberstein B, Pajecki D, Garcia de Brito AC, Gallafrio ST, Eshkenazy R, Andrade CG. Topiramate after adjustable gastric banding in patients with binge eating and difficulty losing weight. Obesity Surgery. 2004;14(6):802-5. Jul. Population. [pmid: 15318986].