# Appendix C. Evidence Tables

Evidence Table 1. Behavioral intervention trials-key question 1

Study Reference | Study characteristics | Patient characteristics | CONSORT Numbers, Retention | Inclusion/Exclusion Criteria | Description of Intervention Groups | Intervention Components | Components Score | Treatment Target Individual vs. Group Tx | Treatment Intensity | Mean Entry Wt | Interv phase 2–11 mo | Interv phase 12–23 mo | Interv phase 24+ mo | Post-Intervention | BMI Change Mean (SD) | Physiological Outcomes | Other anthropomorphic Outcomes (list) | Other Beneficial Outcomes | Adverse Effects (report findings) | Study Quality | Comment (mention which other outcomes significant), other outcomes reported that are not captured in previous columns
Braet et al 2003 | CCT 76 children Residential obesity treatment center Belgium Physician referral Weight loss | Age: 10–17 (Mean=13) 60.5% Female (calc) % White: 93.4% (c) 93.4% White (calc) SES: NR Co-morb: NR | 190 enrolled in residential program (est) 38 selected for study enrollment 38 age-sex-matched controls selected from wait list [underlined: Retention:] I: 31/38 (81.6%) C: 35/38 (92.1%) | [underlined: Incl:] Enrolled in treatment program [underlined: Excl:] Dx of Prader Willi syndrome or mental retardation | I: 10-month residential treatment, covering diet, physical activity, nutrition education, behavioral management/psychological intervention C: Waiting list | D, PA, BT | D=2; PA=2; Tx=2 Total=6 | Child Individual and Group | I: 10 months residential (est 16 hrs/day * 5 days/wk * 44 wks = 3520 hrs) C: None (0 hrs) | [underlined: BMI (Median):] I: 33 (SD NR), C: 33 (SD NR) [underlined: % OW:] I: 75% C: 73% | [underlined: 10-mo] % OW: I: 24% C: 79% p<0.001 [underlined: Wt change:] I: -19 kg (-41.8 lbs) C: +4kg (+8.8 lbs) | NA | NA | NA | | [underlined: Lipids:] No [underlined: Glucose tol:] No [underlined: BP:] No [underlined: Phys fitness:] No | None | NR | No differences in change in height | Fair | Also measured eating psychopathology and child's self-perception in treatment group (but not control)
Carrel et al 2005 | RCT 53 adolescents PE class USA One school Improved body composition, cardiovascular fitness, and insulin sensitivity in OW children | Age: 12–13 (Mean=12.5) 48% Female Race/Eth: NR SES: NR Co-morb: NR | 55 invited 53 baseline eval 53 randomized: I: 27 C: 26 [underlined: Retention, published:] I: 27/27 (100%) C: 23/26 (88.5%) Retention, personal communication: I: 30 C: 23 denom unknown | [underlined: Incl:] age 12–13; BMI>95th %ile (norms not specified) | I: PE class emphasizing non-competative movement activities (e.g. walking, cycline, snow shoeing), maximizing minutes of movement (average 42 min/class), small nutritional component. Class size 12–14 C: PE class, typical competative, team sports emphasis (average 25 min/class, with opportunities for less athletic youth to hold back). Class size 35–40 | D, PA | D=0; PA=2; Tx=0 Total=2 | Child Group | I: 90 sessions (calc) 45 min/session 39 weeks (est) (90*45/60 = 67.5 hrs) C: 90 sessions (calc) 25 min/session 39 wks (est) (90*25/60=37.5 hrs) | [underlined: BMI] I: 32 ± 6 C: 30 ± 4 | [underlined: 9-mo] BMI: I: 33 ± 10 C: 30 ± 5 p=0.10 | NA | NA | NA | [underlined: Post-tx (9-mo)] I: +1 (NR) C: 0 (NR) [underlined: Follow-up:] NR | [underlined: Lipids:] No [underlined: Glucose tol:] Yes [underlined: BP:] No [underlined: Phys fitness:] Yes | % body fat, fat-free body mass | NR | Among treatment participants, measures of “drive for thinness” and “external eating” declined, self-reported ratings of physical appearance, athletic competence, and social acceptance improved. | Fair | Significant improvement in intervention group relative to control group: % body fat, VO2max, oxygen consumption at heart rate of 170 beat/min, fasting insuling level, 1/insulin ration, glucose-insulin ratio
Doyle et al, in press; Celio et al 2006 | RCT 83 adolescents Setting for enrollment/assessment NR, Internet-based intervention USA (CA and MO) Media adverstisements; flyers in schools, medical facilities, and weight-loss organizations; referrals from pediatricians and school nurses Weight Loss and improved eating disorders attitudes/behaviors | Age: 12–18 (Mean 14.5) 62.5% Female 50% White 12.5% Hispanic 26.3% Black 11.3% Other SES: 43.1% parent college graduate or higher Co-morb: NR | 155 assessed for eligibility 72 excluded: 14 did not meet criteria 25 not interested 33 did not attend/complete screening 83 randomized I: 42 C: 41 [underlined: Retention, in-person (personal communication):] I: 28/42 (66.7%) C: 29/41 (70.3%) Retention, incl self-report (published): I: 33/42 (78.6%) C: 33/41 (80.5%) ITT/baseline substitution analysis (published): I: 40/42 (92.2%) C: 40/41 (97.6%) | [underlined: Incl:] Age 12–18; ≥85th %ile for age and sex per CDC 2000 growth charts; Internet access at home or where regular use was possible [underlined: Excl:] Medical condition (e.g. endocrinologic diseases); use of prescription medication assoc with significant weight changes; complications of OW that contraindicated moderate physical activity (e.g. orthopedic disorders); reading ability <6th grade; curr/past eating disorder dx | I: Student Bodies 2 (SB2), Internet-delivered moderated cognitive-behavioral program; basic educational material; guided behavioral modification for wt loss; cognitive exercises for body image issues; gender-specific interfaces and content; on-line journal for recording food intake, physical activity, weight, triggers for body dissatisfaction; individual e-mail contact with moderator; discussion group; monthly newletter to parents C: Basic information on nutrition and physical activity | I: D, PA, BT, PT C: D, PA | D=1; PA=1; Tx=1 Total=3 | Child Individual and on-line Group | I: # sessions varied 60–120 min/wk encouraged 16-wks (est 1 hr/wk*16wks=16 hrs) (est 1 hr rather than 1.5 because partic read avg of 30% of material, and 35% of partic read <10% of material) C: 0 sessions (0 hrs) | BMI SDS: I: 2.19 ± 0.50 C: 2.19 ± 0.44 per CDC 2000 Growth Charts BMI: I: 34.6 ± 7.8 C: 33.9 ± 6.9 | [underlined: 4-mo], BMI SDS: I: 2.11 ± 0.51 C: 2.20 ± 0.43 p=0.03 BMI: I: 34.0 ± 7.6 C: 34.1 ± 6.6 n.s. | | | [underlined: 8-mo (4-mo post-intervention)], BMI SDS: I: 2.10 ± 0.51 C: 2.15 ± 0.48 p=.29 BMI: I: 34.4 ± 7.6 C: 34.3 ± 6.9 n.s. | [underlined: Post-tx (4-mo)] I: -0.6 (NR) C: +0.2 (NR) [underlined: Follow-up (4-mo post-tx)] I: -0.2 (NR) C: +0.4 (NR) | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | Self-image (Shape Concern) | C group showed greater decline in Shape Concern than I group; no other differences in eating disorder pathology | Good
Flodmark et al 1993 | CCT 43 children (plus 50 matched controls) Outpatient referral clinical setting Sweden Screening program in schools Prevention of progression to severe obesity | Age: 10–11 (Mean NR) 52% Female (c) Race/Eth: NR SES: NR Comorb: clinically euthyroid, blood pressures less than 140/90, none with signs of endocrine d/o | Tx groups: 1,906 screened, age 10–11 1,774 parents consent to study partic 49 BMI >23.0 43 randomized: I1 (conventional tx): 19 I2 (I1 + family therapy): 24 C (matched controls): 50 Unclear if controls pulled from same screening population as randomized [underlined: Retention:] I1: 19/19 (100%) i2: 20/24 (83%) C: 48/50 (96%) | [underlined: Incl:] BMI > 23.0 kg/m^2^ | I1: Conventional treatment: dietary counseling with dietitian, monthly visits to experienced pediatrician w interest in wt problems, low fat, 1500–1700 kcal diet prescribed, exercise encouraged I2: Same as above + family therapy C: Matched controls, no treatment | I1: D, PA I2: D, PA, FC C: None | D=0; PA=0; Tx=2 Total=2 (for I2) | I1: Child, parent Individual I2: Family Individual | I1: 0–1 session w dietitian, 5 sessions w/pediatrician minutes NR 14–18 mos (est 6 * 1 hr *2 family member= 12 hrs) I2: 0–1 session w dietitian, 5 sessions w/pediatrician, 6 family therapy sessions minutes NR 14–18 mos (est 12 * 1 hr *2 family member = 24 hrs) C: None (0 hrs) | BMI: (Mean ± SE) I1: 25.5 ± 0.53* I2: 24.7 ± 0.36* C: 25.1 ± 0.35* (similar to 40–50% overweight range) *calculated SD (SE*sqrt(n)): I1: 0.53*sqrt(19)=2.3 I2: 0.36*sqrt(24)=1.8 C: 0.35*sqrt(50)=2.5 | NA | [underlined: Post-tx (14–18 mos):] BMI (Mean ± SE) I1=26.1 ± 0.72* I2=25.0 ± 0.53* C: (data not collected) *calculated SD (SE*sqrt(n)): I1: 0.72*sqrt(19)=3.1 I2: 0.53*sqrt(24)=2.6 | | [underlined: ~48-mo (30–34 mos post-intervention)] BMI: (Mean ± SE) I1=27.1 ± 0.88* I2: 25.8 ± 0.73* C: 27.9 ± 0.61* p=.15 *calculated SD (SE*sqrt(n)): I1: 0.88*sqrt(19)=3.8 I2: 0.73*sqrt(24)=3.6 C: 0.61*sqrt(50)=4.3 | Post-tx (14–18 mos): NA Follow-up (30–34 mo post-tx): I1: +1.6 (NR) I2: +1.1 (NR) C: +2.8 (NR) | Lipids: No Glucose tol: No BP: No Phys fitness: Yes | Triceps, Subscapular, Suprailiac skinfolds | None | NR | Fair | Skinfold measures all showed significantly greater decreases in family therapy group than conventional treatment group.
Gillis et al 2007 | RCT 27 children Primary care clinics in urban Jewish ultra-orthodox neighborhoods Israel 2 primary care clinics Weight loss, improvement in adverse metabolic consequences of obesity and obesity-related attitudes | Age: 7–16 (10.6 (calc)) %Male NR Race/Eth: 100% Jewish SES: NR Co-morb: NR | 27 recruited 27 randomized I: 14 C: 13 [underlined: Retention:] 18/27 (66.7%) overall I: 11/14 (78.6%) C: 7/13 (53.8%) | [underlined: Incl:] Age 7–16; BMI>90th %ile; refered to author (endocrinologist) for eval of obesity | I: Basic discussion on health diet and exercise (at baseline and 3-months); asked to record food/exercise one day/week; weekly phone call to review food/exercise diary and encourage adherence to prescribed plan C: Basic discussion on health diet and exercise (at baseline and 3-months) | D, PA | D=0; PA=0; Tx=0 Total=0 | Child Individual | I: 2 1/2 hr clinic visits + 24 weekly calls (est) # Min/session NR 26 weeks (est) (est 2*.5*hr*2(parent+child) + 24*.25 hr = 8 hrs) C: 2 clinic visits # minutes NR (est 2 hrs) | BMI SDS= I: 1.98 ± 0.21 C: 2.16 ± 0.34 | [underlined: 6-mo] BMI SDS: I: 1.93 ± 0.37 C: 2.23 ± 0.29 p=0.40 BMI SDS change: I: -0.045 ± 0.19 C: 0.075 ± 0.08 p=0.10 | NA | NA | NA | | Lipids: Yes Glucose tol: Yes BP: No Phys fitness: Yes | None | Diet (self-report of change), PA (self-report of change) | NR | Fair | No significant group differences.
Golley et al 2007 | RCT 111 children teaching hospitals Australia media publicity and school newsletters Weight management in prepubertal children | Age: 6–9 (Mean 8.2) 64% Female (calc) 98% White SES: Index of relative socioeconomic advantage slightly above South Australian average Co-morb: NR | 262 Initial phone screening completed 126 eligibility confirmed at medical screening 115 consented 111 completed baseline assessment 111 randomized: I1 (Parenting group): 37 I2 (Parenting + lifestyle): 38 C:(Wait list): 36 Retention: I1: 29/37 (78.4%) I2: 31/38 (81.6%) C: 31/36 (86.1%) | [underlined: Incl:] Age 6–9; OW, per International Obesity Task Force defn); Tanner Stage 1; caregiver willing to attend sessions and able to read and understand English [underlined: Excl]: BMI z-score >3.5; syndromal cause of obesity; medication use that may influence weight; dx of physical or developmental disability; sibling enrolled in study | I1 Parenting skills training, aims to promote parental competence to manage child's behavior with emphasis on dietary and activity behaviors in program examples, pamphlet covering eating and activity behaviors, I2: Parenting + Intensive lifestyle education covering wide variety of topics related to healthy eating, activity, and emotional sequalae of overweight such as self-esteem and teasing. C: Wait-list Control, 3–4 brief phone calls for encourage retention in study | I1: D (minimal), PA (minimal), PT I2: D, PA, PT C: None | D=1; PA=2; Tx=2 Total=5 (for I2) | Parent Group and Individual | I1: 4 group, 7 individual group=120 min indiv=15–20 min 21 wks (calc) (4*2 hrs + 7*.33 hrs =10.33 hrs) I2: 11 group 120 min # wks NR (22 hrs) C: 3–4 5-minute phone calls (0.33 hrs) | BMI: 24.3 ± 2.6 (overall) BMI z-score: I1: 2.76 ± 0.58 I2: 2.74 ± 0.58 C: 2.75 ± 0.39 | [underlined: 6-mo (1-mo post-intervention):] BMI z-score: I1: 2.63 ± 0.53 I2: 2.52 ± 0.53 C: (NR) | | NA | [underlined: 12-mo (7-mos post-intervention):] BMI SDS: I1: 2.56 ± 0.79 I2: 2.43 ± 0.68 C: 2.60 ± 0.57 group*time effect p=0.76 BMI SDS reduction I1: 6% I2: 9% C: 5% (p=0.76, same analysis as above) % increased BMI SDS: I1: 24% I2: 19% C: 45% p<0.03 | | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | Waist circumference | None | Height change did not differ between treatment and control conditions | Good | Waist circumference showed time*group interaction: intervention groups showed decline in waist circumference while control group did not. Also measured satisfaction with care
Graf et al 2006 Graf et al 2005 | Cluster-randomized RCT 276 children School Gemany 7 schools Weight loss | Age: 6–11 (Mean 8.4 (calc)) Sex: NR Race/Eth: NR SES: NR Co-morb: NR | 1678 screened 276 screened OW or obese, randomized at school level I: 121 (46 (38%) agreed to participte in intervention) C: 155 [underlined: Retention:] I: 40/46 (87.0%) (among participants) 75/75 (100%) (among non-participants) C: 144/155 (93.5%) | [underlined: Incl:] Grade 1–4, attending one of randomly selected schools, Overweight or obese (>90th %ile per German percentile graphs of Kromeyer-Hauschild) | I: information on nutrition, health, and behavioral principles of weight management; physical activity; healthy meals; parent meetings to provide information and encourage family activities that support weight management C: Usual school health and P.E. activities | I: D, PA, SA, BT, PT C: None | D=1; PA=2; Tx=1 Total=4 | Child, Parent Group, option for single-family consultations | I: 60 165-min (est) child sessions, 6 105 min parent session 30 weeks (60*2.75 hrs + 6*1.75 hrs = 175.5 hrs) C: No treatment (0 hrs) | BMI I (participants): 22.8 ± 3.6 I (non-partic): 21.1 ± 2.4 C: 21.7 ± 2.7 BMI SDS: I (participants): 1.99 ± 0.52 I (non-partic): 1.81 ± 0.44 C: 1.87 ± 0.41 | [underlined: 9-mo] change in BMI: I (participants): 0.3 ± 1.3 I (non-partic): 0.5 ± 1.3 C: 0.7 ± 1.2 n.s. Change in BMI SDS: I (participants): -0.15 ± 0.26 I (non-partic): -0.09 ± 0.31 C: -0.05 ± 0.27 p=0.03 | NA | NA | NA | Post-tx (9-mo) I (participants): +0.3 (1.3) I (non-partic): +0.5 (1.3) C: +0.7 (1.2) Follow-up: NR | Lipids: No Glucose tol: No BP: Yes Phys fitness: No | Waist circumference | None | None | Fair | Children in both intervention groups (participants and non-partic) showed greated reduction in systolic BP than control group children
Johnston et al, 2007a | RCT 71 adolescents School Invitations sent to homes of all children in 6th and 7th grade in single school Weight loss | Age: 10–14 (Mean 12.5) 55% Female 100% Mexican American SES: NR | 173 Consent forms distributed 102 not randomized (66 did not return consent form, 36 not OW) 71 randomized: I: 46 C: 25 [underlined: Retention:] I: 44/46 (95.6%) C: 22/25 (88.0%) | [underlined: Incl:] 6th or 7th grade at study school; BMI ≥ 85th %ile for age and gender, per 2000 CDC guidelines | I: Intensive Intervention: One class period five days/week, covering nutrition education; structured physical activity; cognitive-behavioral strategies; parent meeting to facilitate family adoption of healthy habits C: Self-Help: Instructed youth and their parents to use a book, Trim Kids; provided 12 weekly activities and maintenance activities | I: D, PA, BT, PT C: D, PA, BT, PT | D=1; PA=2; Tx=1 Total=4 | I: Child, parent Group C: Child, parent Individual | I: 4×/wk exercise for 12 wks, 30–35 min 1×/wk nutrition for 12 weeks, 35–40 min 3 monthly parent meetings 6 (calc) bi-weekly child meetings (5*.58hr*12 wks=35 hrs + 3 + (6*.58) = 41.5 hrs total) C: None (0 hrs) | BMI: I: 27.7 ± 5.0 C: 25.6 ± 3.4 BMI SDS: I: 1.86 ± 0.48 C: 1.64 ± 0.44 Weight, kg: I: 64.9 ± 16.9 C: 58.7 ± 9.1 | [underlined: 6-mo] Change in BMI: I: -0.16 ± 1.05 C: +0.64 ± 0.90 p<0.001 Change in BMI %ile: I: -1.50 ±3.61 C: +0.53 ± 2.12 p<0.01 Change in weight (kg): I: 1.90 ± 2.70 C: 3.49 ± 2.74 p<0.05 | NA | NA | NA | Post-tx (6-mo) I: -0.16 (1.05) C: +0.64 (0.90) Follow-up: NR | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | % Body fat | None | NR | Good | Children in the I group reduced their % body fat more than those in the C group
Johnston et al, 2007b | RCT 60 adolescents School Invitations sent to homes of all children in 6th and 7th grade in single school Weight loss | Age: 10–14 (Mean 12.4 calc) 45% Female 100% Mexican American SES: NR | 181 Consent forms distributed 121 not randomized (55 did not return consent form, 66 not OW) 60 randomized: I: 40 C: 20 [underlined: Retention:] I: 38/40 (95.0%) C: 19/20 (95.0%) | [underlined: Incl:] 6th or 7th grade at study school; BMI ≥ 85th %ile for age and gender, per 2000 CDC guidelines | I: Intensive Intervention: One class period five days/week, covering nutrition education; structured physical activity; cognitive-behavioral strategies; parent meeting to facilitate family adoption of healthy habits C: Self-Help: Instructed youth and their parents to use a book, Trim Kids; provided 12 weekly activities and maintenance activities | I: D, PA, BT, PT C: D, PA, BT, PT | D=1; PA=2; Tx=1 Total=4 | I: Child, parent Group C: Child, parent Individual | I: 4×/wk exercise for 12 wks, 30–35 min 1×/wk nutrition for 12 weeks, 35–40 min 3 monthly parent meetings 6 (calc) bi-weekly child meetings (5*.58hr*12 wks=35 hrs + 3 + (6*.58) = 41.5 hrs total) C: None (0 hrs) | BMI: I: 25.4 ± 4.7 C: 26.7 ± 5.5 BMI SDS: I: 1.6 ± 0.6 C: 1.7 ± 0.6 Weight, kg: I: 59.0 ± 11.8 C: 62.5 ± 16.3 | [underlined: 6-mo (ITT analysis)] Change in BMI: I: -0.99 ± 3.79 C: +1.08 ± 1.0 p<0.001 Change in BMI %ile: I: -3.13 ± 5.35 C: +0.19 ± 1.41 p<0.01 Change in weight (kg): I: -0.29 ± 9.26 C: 4.54 ± 2.82 p<0.05 | NA | NA | NA | NA | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | % Body fat (bioelectrical impedance) | None | NR | Good | Children in the I showed smaller increased in total cholesterol and greater decreases in LDL cholesterol
Kalavainen et al 2007 | RCT 70 children School for CG, IC setting NR School nurses and newspaper articles Weight loss | Age: 6–9 (Mean 8.1) 60% Female 99% Causcian/Finnish 1% Mixed African/Caucasian 4.3% low SES 54.3% high SES Co-morb: NR | 83 families interviewed 70 randomized I: 35 C: 35 [underlined: Retention:] Post-tx: I: 34/35 (97.1%) C: 34/35 (97.1%) 6-mo fup: I: 35/35 (100%) C: 34/35 (97.1%) | [underlined: Incl:] Family with child aged 6–9 20–100% OW [underlined: Excl]: disease or medication causing obesity, obvious movement disturbance, major mental problems in child or parent, any family member participating in weight loss program | I: Family-centered group program based on behavioral and solution-focused therapy for healthy lifestyle; parent and child sessions, child sessions usually involved PA C: Two meetings with school nurse plus booklets for families | D, PA, BT, PT | D=1; PA=2; Tx=1 Total=4 | I: Parent, Child Group C: Parent Child/ Individual | I: 15 90-minute session for parent and child (15*1.5*2=45 hrs total) 6 months C: 2 meetings (est 2 hrs) | BMI I: 23.4 ± 2.6 C: 22.9 ± 2.5 BMI SDS I: 2.6 ± 0.6 C: 2.5 ± 0.6 (per UK 1990 Growth Reference) %OW I: 43 ± 14 C: 41 ± 15 | [underlined: 6-mo] Change in BMI: I: -0.8 ± 1.0 C: 0.0 ± 1.1 p<0.003 Change in BMI SDS: I: -0.3 ± 0.3 C: -0.2 ± 0.3 p<0.022 Change in %OW: I: -6.8 ± 6.2 C: -1.8 ± 6.2 p<0.001 | | | [underlined: 12-mo (6-mo post-intervention)] Change in BMI: I: 0.1 ± 1.2 C: 0.8 ± 1.3 p<0.016 Change in BMI SDS: I: -0.2 ± 0.3 C: -0.1 ± 0.3 p<0.081 Change in %OW: I: -3.4 ± 7.7 C: 1.8 ± 7.8 p<0.008 | Post-tx (6-mo) I: -0.8 ± 1.0 C: 0.0 ± 1.1 Follow-up: I: 0.1 ± 1.2 C: 0.8 ± 1.3 | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | NR | NR | Good | No other target outcomes examined
McCallum et al, 2007 McCallum et al, 2005 | RCT 163 children Oupatient medical clinic Australia GPs recruited from sociodemographically diverse practices Weight loss in moderately overweight children | Age: 5–9 (Mean 7.4) 52% Female Race/Eth: NR SES: practices range from <10th to >90th %ile; median practice close to 50th %ile Comorb: NR | 2112 screened 505 OW or mildly obese 342 excluded or refused, 163 randomized: I: 82 C: 81 [underlined: Retention:] 9-mo fup I: 73 (89%) C: 80 (99%) 12-mo fup I: 70 (85%) C: 76 (94%) | [underlined: Incl:] Age 5–9; attending participating medical practice; classified as OW or mildly obese per International Obesity Task Force definition; not receiving ongoing wt management in secondary or tertiary care program [underlined: Excl:] SDS ≥ 3.0, chromosomal, endocrine, or medical condition/ disability/ medication which could have an impact on wt or growth | I: GP given folder prior to appointment containing child's individualized intervention materials, BMI, and 2-page summary of parent responses from baseline qx. Brief solution-focused intervention to set and record appropriate, healthy lifestyle goals with the family; personalized 20-page “Family Folder” containing topic sheets targeting different areas of behavior change C: Usual care | D, PA | D=1; PA=1; Tx=0 Total=2 | Child, parent Individual | I: 4 sessions minutes NR 12-weeks (assume .5 hrs appointments, 4*.5 hrs*2 fam members=4 hrs total) C: NR (0 hrs) | BMI I: 20.5 ± 2.2 C: 20.0 ± 1.8 BMI SDS I: 2.0 ± 0.5 C: 1.9 ± 0.5 (per UK 1990 Growth Reference) BMI %ile I: 80.8 C: 85.6 | NA | NA | NA | [underlined: 9-mo (6-mo post-intervention)] BMI: I: 21.0 ± 2.6 C: 20.8 ± 2.2 adjusted p=0.25 BMI SDS: I: 1.96 ± 0.64 C: 1.93 ± 0.57 adjusted p=0.12 (per CDC 2000 Growth Charts) [underlined: 15-mo (12-mo post-intervention)] BMI: I: 21.7 ± 3.1 C: 21.2 ± 2.4 adjusted p=1.0 BMI SDS: I: 2.0 ± 0.68 C: 1.92 ± 0.59 adjusted p=0.62 (per CDC 2000 Growth Charts) | Post-tx: NR Follow-up (9 mo post-tx) I: +0.5 (NR) C: +0.8 (NR) Follow-up (12 mo post-tx) I: +1.2 (NR) C: +1.2 (NR) | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | Diet (4-day food diary) PA (4-day activity diary) | “Little evidence of either harm or benefit of the intervention with respect to parent- and child-reported child health status and child-reported body satisfaction and appearance/self-worth.” | Good | % of activity time spent in moderate-vigorous activity and daily nutrition scores better in intervention group than control group at 9 months (nutrition score improved due to substitution of low-fat milk and water for whole milk) Daily nutrition scores better in intervention group than control group at 15 months (nutrition score improved due to substitution of low-fat milk and water for whole milk)
Mellin et al 1987 | design NR (RCT or CCT) 66 adolescents Rural health dept; rural nutrition private practice, suburban medical clinic; urban outpatient clinic USA newspaper announcements, notices to physicians and school personnel Weight loss | Age 12–18 (Mean 15.6) 21% Male 87.9% White 7.6% Hispanic 4.5% Asian or Black (calc) SES: NR Co-morb: NR | 66 sought to enroll 66 randomized I: 37 C: 29 Retention: I: 92% C: 100% | NR | I: SHAPEDOWN program; cognitive, behavioral, affective treatment encouraging successive, sustainable, small modification in diet, exercies, relationship, lifestyle, communicatins, and attitudes. C: no treatment controls | D, PA, BT, PT | D=1; PA=2; Tx=1 Total=4 | Child, Parent Group | I: 14 sessions with adolescents 2 parent sessions 90 min/session 14 weeks (16*1.5 hrs =24 hrs) C: None (0 hrs) | % OW I: 36.5% C: 29.5% per 1973 US Natl Ctr for Health Statistics | [underlined: 3-mo] change in % OW I: -5.9 ± 6.8 C: -0.3 ± 6.6 dependent t-test I: p<0.001 C: n.s. | NA | NA | [underlined: 15-mo (12-mo post-intervention)] change in % OW I: -9.9 ± 15.0 C: -0.1 ± 13.2 dependent t-test I: p<0.01 C: n.s. | | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | depression; self-esteem | Depression improved in treatment group, did not change in control group. | Fair | Treatment group showed improvement on a scale measuring behaviors associated with wt loss or normal wt while control group did not show improvement
Nemet et al 2005 | RCT 54 children Child Health and Sports Center Isreal Self-referral Weight Loss | Age: range 6–16 (Mean 11.1) 43.5% Female Race/Eth: NR (Isreali) SES: NR Co-morb: NR | 54 self-referred to center, randomized: I: 30 C: 24 Retention: 3-mo: I: 24/30 (80.0%) C: 22/24 (91.7%) 12-mo: I:20/30 (66.7%) C: 20/24 (83.3%) | NR, but reported that none of the children had an organic cause for obesity, none received any medication that might interfere with growth or weight control. Unclear if these were exclusion criteria. | I: Twice weekly exercise sessions plus expectation of at least one exercise session at home, 6 semi-monthly parent and/or child meetings with dietician primarily for nutritional counseling, 4 general interest lectures for parents and children on topics related to childhood obesity. C: At least one nutritional counseling session, encouraged to exercise 3 times/week on their own. | I: D, PA, PT C: D | D=1; PA=2; Tx=0 Total=3 | I: Child, Parent Individual C: Child, Parent Individual | I: 28 1-hr exercise sessions 6 30–45 min nutrition counseling 4 lecture, minutes NR 14 wks (calc) (28*1 + 1 hr + .75hr + 4*.75*2)=28+1.75+6=35.75 hrs C: 1 or more nutrition counseling sessions, minute NR (Est 1 hr) | Analyzed sample: BMI: I: 27.7 ± 3.6 C: 28.0 ± 5.2 All randomized: BMI: I: 28.5 ± 4.1 C: 27.8 ± 5.0 BMI percentile: I: 98.2 ± 0.3 C: 97.2 ± 0.7 Weight, kg: I: 63.8 ± 19.1 C: 63.4 ± 22.8 | [underlined: 3-mo] BMI: I: 26.8 ± 3.9 C: 27.6 ± 5.6 p<0.05 Weight, kg: I: 61.0 ± 18.3 C: 64.5 ± 24.1 p<0.05 | | | 15-mo (12-mos post-intervention): BMI: I: 26.1 ± 4.7 C: 28.6 ± 5.8 p<0.05 BMI percentile: I: 92.3 ± 3.0 C: 96.1 ± 1.4 p<0.05 Weight, kg: I: 59.7 ± 17.7 C: 68.6 ± 24.8 p<0.05 | Follow-up (12-mo post-tx): I: -1.5 (NR) C: +0.6 (NR) | Lipids: Yes Glucose tol: No BP: No Phys fitness: Yes | triceps, Subscapular skinfolds | Diet, Physical activity, Sedentary behavior | NR | Fair | At post-intervention (3-mo) I group reported greater increases in the amount of habitual activity, greater reductions in overall and LDL cholesteral. At 1-year followup, I group had greater reductions in body fat, greater amount of habitual activity, and greater improvements in endurance time.
Reinehr et al 2006 | CCT 240 children OW specialty treatment unit in medical facility Germany Recruitment NR Weight loss and cardiovascular disease risk profile improvement | Age: 6–14 (Mean 10.4) 46.5% Female Race/Eth: NR SES: NR Co-morb: 0% endocrine disorders | 240 analyzed: I: 203 C: 37 Retention: I: 174/203 (86%) C: 37/37 (100%) | [underlined: Incl:] Age 6–14; BMI >97th %ile per 2001 German norms; participate in local exercise group for ≥ 8 wks to prove motivation [underlined: Excl:] endocrine disorders, familial hyperlipidemia, or syndromal obesity | I: Multidisciplinary treatment team, program includes physical exercise, nutrition education, behavioral therapy, individual and/or family therapy C: No treatment; Comprised of children who met all criteria but did not participate due to travel distance to the treatment facility | I: D, PA, BT, FC, PT C: None | D=1; PA=2; Tx=2 Total=5 | I: Child, parent, family Individual, group C: None | I: 6 1.5-hr parent group sessions 6 1.5-hr child group sessions 3 1-hr parent sessions 52 exercise session (minutes NR) variable number (est 6) 30-minute individual and/or family therapy sessions (12*1.5hr + 3 + 52*1 hr + 6*.5hr = 76.0 hrs) 1 yr C: None (0 hrs) | BMI: I: 27.0 (26.4, 27.6) C: 26.1 (25.2, 27.8) BMI SDS: I: 2.4 (2.3, 2.4) C: 2.3 (2.2, 2.4) | NA | [underlined: 12-mo] BMI: I: 27.1 (26.4, 27.6) C: 28.1 (27.0, 29.2) p=0.013 (treatment × time effect) BMI SDS: I: 2.1 (2.1, 2.2) C: 2.3 (2.1, 2.4) p=0.007 (treatment × time effect) | | [underlined: 24-mo (12-mos post-intervention)] BMI: I: 28.2 (27.4, 29.0) C: 29.0 (28.0, 30.8) p=0.013 (treatment × time effect) BMI SDS: I: 2.1 (2.1, 2.2) C: 2.3 (2.1, 2.4) p=0.007 (treatment × time effect) | Post-tx (12-mo) I: +0.1 (NR) C: +2.0 (NR) Follow-up (12-mo post-tx): I: +1.2 (NR) C: +2.9 (NR) | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | None | None | NR | Fair | Intervention group showed greater improvement than control group in systolic blood pressure, fasting insulin, homeostatis model assessment of insuline resistance
Rooney et al 2005 | RCT 98 families (353 people, adults and children combined) NR USA NR Increased physical activity | Age: 5–12 (Mean 9.7) 51% Female Race/Eth: NR SES: NR Co-morb: NR | 98 families randomized 87 families analyzed: I1: 28 families I2: 30 families C: 29 families [underlined: Retention:] 87 families (88.8%) 316 people (89.5%) Individual children (personal communication): I1: 21 I2: 24 C: 27 (denominators unknown) | [underlined: Incl:] At least one child aged 5–12 with BMI over 84th %ile; at least one adult willing to participate. (Siblings also invited to participate) | I1: Pedometer group given a pedometer, instructed in its use and told to walk 10,000 steps daily for 12 weeks; biweekly newsletters containing informative articles and fun activity tips. I2: Pedometer + education group; above, plus education sessions covering nutrition, physical activity, other parenting issues. C: Not described | I1: PA I2: D, PA, PT C: Not described | D=1; PA=1; Tx=0 Total=2 (for I2) | Family NR | I1: #session, min NR 12 wks (est 1 hr pedometer instruction*3 fam members=3 hrs) I2: 1 session pedometer instruction (est 1 hr) 6 1-hr wt loss education sessions (est (1hr+7 hrs)*3 fam members=21 hrs) 12 wks C: NR (est 0 hrs) | BMI %ile: I1&I2: 80.8 C: 85.6 (per CDC growth charts, year not specified) | [underlined: 3-mo] BMI %ile: I1&I2: 82.3 C: 85.0 p=0.42 | NA | NA | [underlined: 9-mo (6 mos post-intervention)] BMI %ile: I1&I2: 80.9 (SD NR) C: 84.3 (SD NR) p=0.33 Change in BMI %ile: I1&I2: +0.31 (SD NR) C: -1.32 (SD NR) p=0.28 | 9-mo (personal communication): I: -0.87 ± 1.27 C: -0.43 ± 1.09 | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | Physical activity | NR | Fair | No significant group differences at 9 months
Saelens et al 2002 | RCT 44 adolescents Primary care clinical setting USA Flyers in pediatric clinic waiting room, pediatrician encouragement to participate Weight loss | Age: 12–16 Mean 14.2 ± 1.2 40.9% Female 70.5% White 15.9% Hispanic 4.5% Black 2.3% Asian 6.8% Multi-ethnic SES: Median household income $60K–69K Co-morb: NR | 59 scheduled baseline assmt 47 complete baseline assmt 44 met wt criteria and were randomized I: 23 C: 21 Retention: I: 18/23 (78%) complete fup C: 19/21 (90%) fup | [underlined: Incl:] Age 12–16; 20–100% above median (50%ile) for BMI for sex and age per CDC 2000 growth charts; interested in weight control, but not currently engaged in another wt control program; otherwise healthy as determined by pediatrician | I: Healthy habits intervention: computerized assessment; meeting with pediatritian to discuss results of assessment, develop action plan; 10–20 minutes counseling calls; mailed participant manual in three different mailings (part of manual mailed each time); encouraged self-monitoring of food intake and physical activity C: Typical care intervention: 5–10 minute meeting with pediatrician assessing motivation and providing (non-tailored) information on healthy eating and physical activity | I: D, PA, SA, BT C: D, PA (brief) | D=1; PA=1; Tx=0 Total=2 | Child Individual | I: 1 pediatrician session, 11 phone calls Pediatrician visit 5–10 minutes, phone calls 10–20 minutes 14–16 wks total (10 min + 11*20 min = 230 min = 3.8 hrs) C: 1 pediatrician session 5–10 minutes 1 day (.2 hrs) | BMI I: 31.0 ± 3.5 C: 30.7 ± 3.1 % OW I: 62.0 ± 20.5 C: 62.3 ± 17.4 (per 2000 CDC growth charts) | [underlined: 4-mo] BMI z-score: I: 2.15 (SD NR) C: 2.02 (SD NR) (est from graph) p=<0.03 for overall time*treatment effect BMI: I: 30.9 ± 3.8 C: 31.8 ± 3.4 p=NR % OW: I: 59.8 ± 21.8 C: 66.2 ± 18.6 p=NR | NA | NA | [underlined: 7-mo (3-mo post intervention)] BMI z-score: I: 2.15 (SD NR) C: 2.01 (SD NR) (est from graph) p=<0.03 for overall time*treatment effect BMI: I: 31.1 ± 4.5 C: 32.1 ± 3.8 p=NR % OW: I: 59.6 ± 24.6 C: 66.4 ± 20.1 p=NR | Post-tx (4-mo): I: -0.1 (NR) C: +1.1 (NR) Follow-up (3 mo post-tx): I: +0.1 (NR) C: +1.4 (NR) | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | Diet, Physical activity, Sedentary behavior, problematic eating/eating disorder psychopathology | problematic eating/eating disorder psychopathology did not differ between treatment and control groups | Good | No significant group differences at 7 months in secondary outcomes
Savoye et al 2007 | RCT 174 children and adolescents pediatric obesity clinic USA NR Changes in BMI, body composition, insulin sensitivity, blood pressure, and lipid profiles | Age: 8–16 (Mean 12.1 (calc)) 60.9% Female (calc) 36.8% White 24.7% Hispanic 38.5% Black (all calc) SES: NR Co-morb: 0% Diabetes | 284 assessed 271 met inclusion criteria 209 consented and randomized I: 105 C: 69 [underlined: Retention:] I: 86/105 (81.9%) 6-mo intervtn/assessmt C: 49/69 (71.0%) 6-mo intervtn/assessmt I: 75/105 (71.4%) 12-mo intervtn/assessmt C: 44/69 (63.8%) 12-mo intervtn/assessmt | Incl: BMI >95th %ile; age 8–16; English-speaking; caregiver willing to participate. Excl: diabetes; severe psychiatric disorder or cognitive deficits; serious medical condition that would preclude them from participation; taking medications that could cause significant wt gain; using medications for wt loss; involved in wt management program | I: Bright Bodies Weight Management, twice weekly exercise program; weekly nutrition education and behavior modification class. C: pediatric obesity clinic visit every 6 months for diet and exercise counseling and brief pschosocial counseling with social worker. | I: D, PA, BT, PT | D=1; PA=2; Tx=2 Total=5 | Child, Parent Group | I: 65 sessions (calc) 90 min/session 52 weeks (65*1.5=97.5 hrs) C: 2 sessions (calc) min/sessin NR 52 weeks (est) (2*1 hr=2 hrs) | BMI I: 35.8 ± 7.6 C: 36.2 ± 6.2 Wt, kg I: 87.0 ± 25.1 C: 91.2 ± 23.3 | [underlined: 6-mo] Change in BMI I: -2.1 (-2.6, -1.5)* C: 1.1 (0.4, 1.8)* p<0.001 *SD calc: I: 1.1*2.61=2.87 C: 1.4*2.1=2.97 Change in Wt, kg I: -2.6 (-4.2, -0.9) C: 5.0 (2.9, 7.2) p<0.001 | [underlined: 12-mo] Change in BMI I: -1.7 (-2.3, -1.1)* C: 1.6 (0.8, 2.3)* p<0.001 *SD calculated: I: 1.2*[sqrt(105)/(2*1.96)]=3.13 C: 1.5*[sqrt(69)/(2*1.96)]=3.18 Change in Wt, kg I: 0.3 (-1.4, 2.0) C: 7.7 (5.3, 10.0) p<0.001 | NA | NA | Post-tx (12-mo): I: -1.7 ± 3.14 C: +1.6 ± 3.17 Follow-up: NR | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | % Body fat, Body fat mass | | Found no difference between treatment and control group in changes in height at 6 months or 12 months | Good | Also significant were: % body fat at 6-mo & 12-mo; body fat mass at 6-mo & 12-mo; total cholesterol at 6-mo & 12-mo; fasting insulin at 6-mo & 12-mo; homeostatsis model assessment of insulin resistance, 6-mo & 12-mo
Senediak et al 1985 | 45 children Setting NR USA Media ads + publicity to medical professionals Weight loss | Age: 6–12 (calc) (Mean 10.3) 34% Female (est) Race/Eth: NR SES: NR Co-morb: NR | 45 randomized: I1 (rapid schedule): 12 I2 (standard schedule): 12 C1 (attention control): 11 C2 (wait-list): 10 (not reported here) Retention: I1: 66.7% fup I2: 83.3% fup C1: 63.6% fup | Incl: At least 20% overweight for height, age, and sex Excl: Height not below 20th %ile for age; no hx of psychiatric contact; no hx of endocrine or metabolic disorders; not in special education | I1: rapid schedule BT I2: gradually decreasing schedule BT C1: relaxaion, mood management control C2: wait list (not reported here) | I1&I2: D, PA, BT, PT C: PT | D=1; PA=1; Tx=1 Total=3 | Child, parent Group | All: 8 90-minute sessions (12 hrs) I1&C1: 4 wks I2: 15 wks | BMI I: 20.5 ± 2.2 C: 20.0 ± 1.8 BMI SDS I: 2.0 ± 0.5 C: 1.9 ± 0.5 (per UK 1990 Growth Reference) BMI %ile I: 80.8 C: 85.6 | NA (report post-treatment, but since post-tx point different (1 mo vs 3.5-mo), will only report post-intervention follow-up | | | %OW I1: 19.9 ± 14.2 I2: 16.6 ± 11.5 C1: 30.8 ± 10.4 p<0.05 Wt, kg I1: 49.5 ± 7.4 I2: 48.6 ± 11.1 C1: 44.8 ± 4.9 p<0.05 | | Lipids: No Glucose tol: No BP: No Phys fitness: No | Subscapular skinfold | NR | NR | Fair | I groups showed greater reductions in skinfold than C1

Evidence Table 2. Supplementary behavioral trials for key question 2 and 5

Study Reference | Study Characteristics | Patient Characteristics | CONSORT Numbers, Retention | Inclusion/Exclusion Criteria | Description of Intervention Groups | Treatment Target Individual vs. Group Tx | Treatment Intensity | Mean Entry Wt | Interv phase 2–11 mo | Interv phase 12–23 mo | Interv phase 24+ mo | Post-Intervention | Other anthropomorphic Outcomes | Study Quality | Comment, other outcomes reported that are not captured in previous columns
| Effect of Additional Maintenance support (KQ2)
Deforche et al 2005 | 20 adolescents Phone and mail follow-up after residential treatment Australia Youth who had completed residential OW treatment recruited Increase physical activity, decrease sedentary behaviors | Age: 11–18 (Mean 16.3) 50% Female Race/Eth: NR SES: NR Co-morb: NR | 20 recruited 20 randomized Retention: Unclear, but appears from degrees of freedom in analyses that there was 100% fup | [underlined: Incl]: Completed 10-mo residential treatment programme; not involved in another study | I: Bi-weekly calls initially, then every 3 wks; youth sent weekly diary of physical and sedentary behaviors; goal-setting and problem solving; reward system for physical activity C: Monthly check-ups | Child Individual | I: 10 calls (calc) 5–10 min/call 21 wks C: 3 check-ups # minutes NR 13 wks (calc) | % OW I: 31% C: 31% (est from graph, per 2000 Flemish growth charts (ref 10)) | NA | [underlined: 16.5 mos (calc, 6.5 mos after end of residential treatment, at end of maintenance trial)] %OW I: 40% C: 45% p<0.05 (est from graph) | NA | NA | None | Fair | I group showed greater increases in total activity and moderate-to-high intensity activites compared with C group; No diffs in change in low-intesity activities; I group played computer games less often than C group; No diffs in change in TV viewing
Wilfley et al, 2007 | RCT 150 children University USA media announcements/ ads, physician referral Weight loss | Age: 7–12 (Mean 9.9 (calc)) 69.3% Female (calc) 7.3% Black (calc) 70.7% White (calc) 18.7% Hispanic (calc) 3.3% Other (calc) 50.7% Maternal education college or higher (calc) Co-morb: NR | 1,028 Contacted clinic 325 Attended orientation 236 Interviewed 32 Excluded (18 not interested; 14 did not meet inclusion crit) 204 Began wt loss treatment 54 not randomized due to dropped out of wt loss program (44), not interested/available for maintenence trial (10) 150 randomized to maintenance strategy: I1 (behavioral): 51 I2: (social facilitation): 50 C: 49 Retention: 1-yr fup: I1: 86.2% I2: 86.0% C: 85.7% 2-yr fup: I1: 84.3% I2: 86.0% C: 77.6% | [underlined: Incl:] Age 7–12; 20% to 100% OW per CDC 2000 growth charts; parent with BMI >25 [underlined: Excl:] child or parent currently in psychological or wt loss treatment; child/parent using appetite or weight-affecting medications; child/parent had psychiatric disorder that would interfere with participation (e.g., eating disorder, psychosis) | I1: Behavioral Self Management, including problem solving, goal-setting, and relapse prevention I2: Social facilitation, including social support skills (e.g. facilitating physical activities with friends, friendships with active children), coping with teasing, body esteem C: Usual care (discontinued contact after wt loss program) | Child, parent Group and individual (parent and child together) | I1&I2: 16 1-hr maintenance sessions over 16 wks + 20 hrs over 5 months from initial wt loss program 32 hrs total C: 20 hrs over 5 months from initial wt loss program 20 hrs total | BMI SDS (at tx baseline) I1: 2.17 ± 0.28 I2: 2.26 ± 0.27 C: 2.17 ± 0.34 %OW (at tx baseline) I1: 61.8 ± 17.4 I2: 68.1 ± 17.6 C: 63.3 ± 20.8 BMI SDS (at randomization to maintenance program) I1: 1.99 ± 0.39 I2: 2.03 ± 0.51 C: 2.07 ± 0.38 %OW (at randomization to maintenance program) I1: 49.7 ± 16.2 I2: 56.5 ± 20.1 C: 54.2 ± 20.3 (all per CDC 2000 growth charts) | NA | [underlined: 9-mo from start of wt loss tx (immediately after maintenance intervention)] BMI SDS: I1: 1.90 ± 0.35 I2: 1.99 ± 0.48 C: 2.04 ± 0.37 I1 vs. C, p=0.01 I2 vs. C, p=0.009 I1&I2 vs. C p=0.003 % OW: I1: 49.1 ± 16.9 I2: 56.2 ± 21.8 C: 57.9 ± 21.2 I1 vs. C, p=0.003 I2 vs. C, p=0.006 I1&I2 vs. C p=0.001 | | [underlined: 17-mo from start of wt loss tx (8 mos after end of intervention)] BMI SDS: I1: 1.99 ± 0.39 I2: 2.03 ± 0.51 C: 2.07 ± 0.38 I1 vs. C, p=0.19 I2 vs. C, p=0.06 I1&I2 vs. C p=0.07 % OW: I1: 57.0 ± 21.5 I2: 61.2 ± 24.5 C: 61.6 ± 23.3 I1 vs. C, p=0.19 I2 vs. C, p=0.08 I1&I2 vs. C p=0.08 [underlined: 29-mo from start of wt loss tx (20 mos after end of intervention)] BMI SDS: I1: 1.98 ± 0.48 I2: 2.02 ± 0.50 C: 2.11 ± 0.36 I1 vs. C, p=0.51 I2 vs. C, p=0.17 1&I2 vs. C p=0.25 % OW: I1: 59.6 ± 24.1 I2: 62.6 ± 25.9 C: 64.8 ± 22.9 I1 vs. C, p=0.97 I2 vs. C, p=0.25 I1&I2 vs. C p=0.50 | None | Good | No other significant findings in outcomes listed here
| Importance of Organized Physical Activity Session (KQ5)
Epstein et al 1985a | RCT 23 girls Setting NR USA Physician and school nurse referal, response to media coverage Weight Loss | Age: 8–12 (Avg NR) 100% Female Race/Eth: NR SES: NR Co-morb: NR | 22 families enrolled, one with 2 children Group assignment NR | at least 20% overweight for height and age; no medical problems that would contra-indicate weight loss, exercise, or fitness testing; parent willing to participate | I1: Behavioral wt loss program + organized PA sessions I2: Behavioral wt loss program without organized PA sessions | Child, Parent Group | I1: 18 beh tx sessions over 12 mos + exercise 3×/wk (1.5 hrs est) for 6 wks + 10 monthly exercise sessions assume 1-hr sessions=18*2fam memb+ 3*1.5*6wks+10=36 + 27 + 10 = 65 hrs total I2: 18 beh tx sessions over 12 mos 18*2 fam members=36 hrs total | %OW: I1: 48.0 ± 23.2 I2: 48.1 ± 17.6 | 6-mo %OW: I1: 20.5 ± 22.6 I2: 29.3 ± 22.3 p<0.05 Weight, kg: I1: 47.0 ± 17.0 I2: 50.1 ± 19.4 p<0.05 | 12-mo %OW: I1: 22.6 ± 29.3 I2: 29.4 ± 22.5 n.s. Weight, kg: I1: 49.9 ± 19.1 I2: 52.6 ± 19.0 n.s. | NR | NA | None | Fair | I1 greater physical work capacity at 12-mo than I2.
Gutin et al 2002 Kang et al 2002 | RCT 80 adolscents Research clinic USA Flyers sent to parents of children attending nearby schools, community and hospital newspaper ads improve cardiovascular fitness, body fat, visceral adipose tissue | Age: 13–16 (Mean 14.8) 67.5% Female 68.8% Black 31.2% White SES: NR Co-morb: NR | 80 Randomized (N in each group NR) Retention (overall): 59/80 (73.8%) fup | [underlined: Incl:] Age 13–16; triceps skinfold thickness > 85%ile for sex, ethnicity, and age; not involved in any other weight control or exercise program; not restricted as to physical activity | I1: lifestyle education only (LSE), information on diet, physical activity, psychosocial skills, problem-solving, coping skills I2: LSE + moderate PA I3: LSE + high intensity PA | Child Group | I1: 19 (est) 1-hour sessions I2: I1 + 171 (est) 43-min PA sessions 19 + 171*.75 = 147.25 hr total I3: I1 + 171 (est) 29-min PA sessions 19 + 171*.30 = 104.5 hr total | Overall 44.5% body fat (group means NR) | 8-mo Change in % body fat per DXA I1: -0.11 ± 0.57 I2: -1.42 ± 0.84 I3: -2.85 ± 1.25 p=0.11 | NA | NA | | Visceral Adipose Tissue (VAT); Triacylglycerol; Apolipoprotein levels | Fair | Significant group differences in cardiovascular fitness, triacylglycerol, ratio of total cholesteral to HDLC, LDL size, and diastolic blood pressure.
Woo et al, 2004 | RCT 82 children Setting NR Hong Kong School teachers To improve obesity-related vascular abnormalities | Age: 9–12 (Mean 9.9) 34% Female Race/Eth: NR SES: NR Co-morb: 0% DM | 170 children and parents indicated interest in study 151 evaluated and found eligible 82 randomized: I1 (diet only): 41 I2 (diet + exercise): 41 Retention: NR | [underlined: Incl:] Age 9–12; no known medical illness; no alternative cause for obesity; resting brachial artery diameter >2.5 mm [underlined: Excl:] family hx of premature cardivascular disease; taking regular medications or vitamin supplementation; hx of diabetes, renal disease, cardiovascular disease; sexual maturity > Tanner stage 2 | I1: Diet I2: Diet + Exercise training | I1&I2: Child, parent NR | I1: 32 sessions (calc), minutes NR 1-year est 32 hrs total I2: Above, + 58 75-min workout sessions est 32 + 58*1.25 = 104.5 hrs total | BMI I1:24.5 ± 2.9 I2: 25.4 ± 3.1 Weight, kg I1: 50.3 ± 8.5 I2: 54.6 ± 9.5 | | | | 12-mo (10.5 mo post-intervention) BMI I1:24.5 ± 3.3 I2-discontinued exercise program: 26.1 ± 4.2 I2-continued exercise program: 25.4 ± 2.4 (all changes from baseline n.s.) | %body fat, hip-waist ratio | Fair | No direct comparisons made between the 3 groups, interpretation of pattern of differences from baseline hampered by lack of randomized (or unbiased) assignment between those continuing and not continuing exercise—instead self-selected.
| Importance of Cognitive-Behavioral Techniques
Epstein 1985b | RCT 24 children Setting NR USA Physician referral, school nurse, media advertisements Weight loss | Age: 5–8 (NR) 100% Female Race/Eth: NR SES: NR Co-morb: NR | 24 accepted into program and randomized 5 dropped out after preliminary meeting. I1: 8 I2: 11 | NR | I1: Education + BT (PA-) I2: Education only | Child, parent NR | I1&I2: Child: 3×/wk for 5 wks + preliminary session + 9 monthly maintenance session Parent 5 weekly meetings + same preliminary and maintenance session as child assume all session 1 hr, 15 + 1+ 9 + 5 + 1 + 9 = 40 hrs total | BMI I1: 22.8 ± 2.6 I2: 22.7 ± 3.0 %OW I1: 41.9 ± 13.6 I2: 39.2 ± 17.1 | 8-mo (during maintenance phase) BMI I1: 19.2 ± 2.7 I2: 21.2 ± 3.3 p<0.05 %OW I1: 18.2 ± 16.2 I2: 27.6 ± 17.1 p<0.05 | 12-mo (after maintenance phase) BMI I1: 19.1 ± 2.8 I2: 21.4 ± 3.3 p<0.05 %OW I1: 15.6 ± 15.2 I2: 28.0 ± 16.7 p<0.05 | NR | NA | None | Fair | I1 showed greater improvement in eating habits (not defined) compared with I2
Williamson et al 2005 Williamson et al 2006 White et al, 2004 | RCT 57 adolescents research clinic USA Media stories and advertisements Weight Loss | Age: 11–15 (Mean 13.2) 100% Female 100% Black SES: NR Co-morbidities: NR | 230 expressed interest 116 met BMI crit, scheduled for full screening 96 completed screening interview 61 met criteria and were randomized 57 completed full baseline assessment at began intervention: I1: 29 I2: 28 Retention 6-mo: I1: 93.1% fup I2: 82.1% fup 24-mo: I1: 75.9% fup I2: 64.3% fup | Incl: Age 11–15; African American; Female; BMI > 85th %ile for age and gender per 1999 NHANES norms; at least one biological parent BMI >30; one parent with BMI >27 willing to participate in study; family willing to pay $300 out-of-pocket (plus use study-provider coupon) to purchase computer; electricity and functional telephone line in the home Excl: adolescent or parent have insulin-dependent diabetes, eating disorder, significant mental health problem, or serious health proble; adolescent or parent pregnant; other problems that might interfere with family's participation | I1: Education only, passive face-to-face and internet education I2: Behavioral, interactive face-to-face and internet behavioral counseling programs | Child, parent Individual nutrition couseling, e-mail contact | I1&I2: 4 face-to-face sessions (minutes NR) variable time on internet, e-mail contact with counselor 12 weeks est 4 hrs face-to-face + 12 hrs internet = 16 hrs total | BMI I1: 37.3 ± 8.2 I2: 35.3 ± 7.6 % body fat: I1: 46.2 ± 6.4 I2: 45.5 ± 8.3 | -1.12%; -0.19 kg/m2 | NR | NR | [underlined: 6-mo (3-mo post intervention)] Change (±SE) in BMI: I1: +0.65 ± 0.23 I2: -0.19 ± 0.24 p<0.05 Change (±SE) in % body fat: I1: +0.43 ± 0.47 I2: -1.12 ± 0.47 p<0.05 Change (±SE) in weight, kg: I1: +2.29 ± 0.56 I2: +0.70 ± 0.59 n.s. [underlined: 24-mo (21-mo post intervention)] Change (±SE) in BMI: I1: +1.2 ± 0.65 I2: +0.7 ± 0.66 n.s. Change (±SE) in % body fat: I1: +0.84 ± 0.72 I2: -0.08 ± 0.71 n.s. Change (±SE) in weight, kg: I1: +6.3 ± 1.6 I2: +4.4 ± 1.7 n.s. | None | Good
| Varying degrees of family involvement
Golan et al, 2006 | RCT 37 children (32 families) Setting NR Isreal Newspaper advertisement Weight loss | Age: 6–11 (Mean 8.7) 54% Female Race/Eth: NR SES: NR Co-morb: NR | 102 families responded to advertisement 32 families met inclusion criteria 32 families randomized: I1 (Parent only): 14 I2: (Parent + Child): 18 Retention: 100% attended follow-up meeting, presume this means they all had at least 12 month fup data Retention in tx program: I1: 76.5% I2: 95% | [underlined: Incl:] Age 6–11; >20% OW (per Cole et al, 2000); parents agree to attend meetings [underlined: Excl:] Current participation of any family member in wt-loss program; restrictions on physical activitiy for children or parents; dx of psychiatric or major endocrine pathology | I1: Only attended by parents: family-based, encouraging health eating patterns, encreased physical activity, reduced sedentary activity; coping techniques for parents to foster authoritative feeding style, de-emphasize thinness, and nurture children emotionally I2: Same content, classes attended by children and parents | I1: Parent I2: Parent, Child I1&I2: Group | I1&I2: 16 sessions 40–50 min/session 6 months est 16*.75=12 hrs total | BMI I1: 24.2 ± 3.0 I2: 24.3 ± 3.6 % OW: I1: 44.0 ± 22.1 I2: 48.5 ± 18.1 BMI SDS: I1: 2.0 (SD NR) I2: 2.1 (SD NR) | 6-mo %OW: I1: 37.5 ± 22.0 I2: 46.1 ± 17.8 p<0.02 | | | [underlined: 12-mo (6-mo post intervention)] %OW: I1: 34.4 (SD NR) I2: 48.9 (NS NR) p<0.05 | None | Good | No others listed here were significant
Israel et al 1985 | RCT 33 children Setting: NR USA Recruitment through letters to pediatricians and school nurses and newspaper ads Weight loss | Age 8–12 (Mean 10.6) 30.3% Male Race/Eth: NR SES: NR Co-morb: NR | 33 randomized I1: 12 I2: 12 C: 9 (not reported here) Retention at 1-yr fup: Unclear if controls later assigned to I1 or I2 were added in, if this really represents retention as originally assigned I1: 9/12 (75.0%) I2: 11/12 (91.7%) | Age 8–12; at least 20% overweight for height per NCHS 1977 norms; able to obtain medical clearance from doctor | I1: BT only, covering diet, physical activity, problem solving, stimulus control/cues, rewards I2: BT + parent training in child management C: Wait list controls | Child, parent Group, individual phone calls | I1: 9 90-min session over 9 weeks, phone calls between session and monthly from mos 4–12 (# and minutes NR) 6 “brief” ploblem-solving discussions + weigh-in 9*1.5*2 + 8*.25 + 8*.25 + 6*.5*2 = 27+4+4+6 =41 hr total I2: above + 2 60-min parent training session est 43 hrs total | % OW I1: 53.13% I2: 45.88% C: 56.02% | NR | [underlined: 12-mo] [underlined: % OW] I1: 45.5 ± 21.2 I2: 40.4 ± 32.9 p<0.045 for treatment*time, including 9-week assessment (I1 showed continued improvement, I2 showed relapse) | NR | | None | Fair
Wadden et al 1990 | RCT 47 adolescent girls Setting NR USA newspaper ads, school nurses referral, physician referral Weight loss | Age 12–16 (Mean 13.8) 0% Male 100% Black SES: 64% single-parent homes economically “lower- to lower-middle class” Co-morb: NR | 58 interviewed 47 randomized: I1 (child only): 19 I2 (mother child together): 14 13 (mother child separately): 14 Retention: 31/36 (86%) fup overall, no group differences in retention | [underlined: Incl:] Age 12–16; ≥10 kg overweight for age, sex, and height; free of medical conditions that would affect body weight; mothers agree to participate | I1: Child alone, information on diet, physical activity, eating process, behavior modification I2: Mother and child seen together, same program as above I3: Mother and child seen separately, same program as above | I1: Child I2&I3: Child, parent All: Group | All: 22 1-hr sessions 10 months | BMI I1: 35.1 ± 5.4 I2: 32.8 ± 3.8 I3: 36.7 ± 3.7 % body fat: I1: 41.6 ± 3.5 I2: 39.5 ± 5.2 I3: 40.4 ± 5.6 | [underlined: 10-mo] Overall mean BMI 35.4, not different from baseline, no group differences | NA | NA | NA | None | Fair
Israel et al 1994 | RCT 34 families Setting NR USA Media articles, letters to pediatricians and school nurses Weight loss | 8–13 (Mean NR) Sex: NR Race/Eth: NR SES: NR Co-morb: NR | 34 randomized I1 (Standard Tx): 18 I2 (Enhanded Child Involvement: 16 Retention: I1: 11/18 (61.1%) I2: 9/16 (56.2%) | [underlined: Incl]: Age 8–13; at least 20% overweight for weight, height, and sex; parent willing to participate; medical clearance from physician [underlined: Excl]: Physical or psychological difficulties suggesting that the program would be inappropriate | I1: Standard treatment (parents primarily responsible) I2: Enhanced Child Involvement (children encouraged to take more active role) | I1: Parent I2: Parent, Child I1&I2: Group | I1&I2: 17 1.5-hr sessions, parent + child 26 weeks | I1: 46.0% OW I2: 48.1% OW | 6-mo %OW: I1:33.4 ± 17.0 I2: 32.6 ± 17.3 n.s. | -0.8% | 6.4% | [underlined: 12-mo (6-mo post intervention)] %OW: I1: 45.2 ± 23.9 I2: 42.3 ± 22.5 n.s. 36-mo (30-mo post intervention) %OW: I1: 52.3 ± 24.4 I2: 43.3 ± 21.2 n.s. | Triceps skinfold | Fair | No other outcomes listed here were significant
Golan et al 1998 | RCT 60 children Setting NR Israel Schools Weight loss | Age 6–11 (Mean 9.0) 38.3% Male Race/Eth: NR (Israeli) SES: “Middle class” Co-morb: NR | 160 identified as obese 140 met inclusion criteria 60 agree to participate 60 randomized: I1 (parent target): 30 I2: (child target): 30 Retention: I1 29/30 (96.7%) fup I2 21/30 (70.0%) fup p<0.02 for group difference | [underlined: Incl:] Age 6–11; > 20 % overweight for age, height and gender; both parents living at home [underlined: Excl:] Hx of psychiatric disorder | I1: conventional: children responsible for own wt loss, counseling regarding diet, physical activity, behavior modification I2: parents exclusive agents of change, counseling regarding diet, physical activity, behavior modification | I1: Child I2: Parent, family I1&I2: Group | I1: 30 60-min session 12 months total 30 hrs total I2: 14 60-min group sessions for parents; 5 15-min individual session for families 12 months total 15.25 hrs total | %OW: I1: 39.1 ± 3.8 I2: 39.6 ± 3.0 | NA | [underlined: 12-mo] %OW: I1: 31.5 (SD NR) I2: 25.1 (SD NR) p<0.01 Change in %OW I1: -8.1 (SD NR) I2:-14.7 (SD NR) p<0.03 | NR | [underlined: 18-mo (6-mo post-intervention):] % of weight loss maintained: I1: 40% I2: 85% p<0.05 [underlined: 24-mo (12 mos post-intervention):] %OW: I1: 26.0 I2: 39.8 p<0.01 Change in %OW: I1: 0% I2: -13.6% p<0.05 [underlined: 36-mo (24-mos post-intervention):] %OW: I1: 42.0 I2: 24.6 p<0.01 Change in %OW: I1: +2.9% I2: -15.0% p<0.01 [underlined: 7-yr (6-yrs post-intervention):] %OW: I1: 18.9 I2: 10.4 p<0.05 Change in %OW: I1: -20.2% I2: -29.0% p<0.05 | None | Fair

Evidence Table 3. Pharmacological intervention trials

Study Reference | Study Characteristics | Patient Characteristics | CONSORT Numbers Retention | Inclusion/Exclusion | Description of Intervention Groups | Dose/Duration | Mean Entry Wt | Interv phase 6–11 mo | Interv phase 12–23 mo | Interv phase 24+ mo | Post-Intervention | Physiological Outcomes Reported | Other anthropomorphic Outcomes | Adverse Effects | Study Quality | Comment (mention which other outcomes significant
| Sibutramine
Berkowitz et al 2003 Budd et al 2007 | RCT 82 adolescents University-based specialty research clinic USA Source NR Weight loss March 1999– August 2002 Funding: NIH; Hospital; Pharmaceutical | Age: 13–17 (Mean 14.1) 67.1% Female 54.9% White 41.5% Black 3.6% Other SES: NR Co-Morb: 0% DM | 146 Evaluated 64 Excluded due to: psychiatric condition (24), not interested (21) Unable to attend group meetings (12), medical conditions (2), other (7) 82 randomized: I: 43 C: 39 Retention: I: 93% follow-up C:87.2% follow-up | [underlined: Inclusion]: Age 13–17; BMI 32–44 [underlined: Exclusion:] cardiovascular disease; Type 1 or 2 diabetes; major psychiatric disorder; pregnancy; use of wt-loss medication; weight loss of ≥ 5kg in past 6 mos; use of medication associated with wt gain; use of medication contraindicated with use of sibutramine; cigarette smoking | I: Sibutramine + Behavior Therapy C: Placebo + Behavior Therapy | Week 1: placebo Week 2: 5 mg/day Wks 3–6: 10 mg/day Wks 7–6 mos: 15 mg/day (decreased dose if systolic or diastolic BP increased by ≥10 mm Hg or pulse rate increased by ≥15% from baseline for 2 consecutive visits | BMI: I: 37.5 ± 4.0 C: 38.0 ± 3.6 BMI SDS: I: 2.4 ± 0.2 C: 2.5 ± 0.2 | [underlined: 6-mo] % change in BMI: I: -8.5% ± 6.8% C: -4.0% ± 5.4% p=0.001 change in BMI SDS: I: -0.2 ± 0.2 C: -0.1 ± 0.1 p=0.003 | NA | NA | NA | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No Pulse: pulse rate higher in IG compared to CG by 5–6 bpm at 3 mos (P < 0.001) and 6 mos (p=0.007) SBP: at 3 mos, mean SBP was increased in IG (1.8 (10.7)mmHG) and decreased in CG (-3.6(8.6); ES 0.55 (95% CI 0.10–1.00);p=0.02) at 6 mos, IG: 0.4 (9.0)mmHg CG: -4.0 (8.9)mmHg ES: 0.45 (-0.02, 0.92)p=0.06 DBP: no differences between groups Elevated BP: I: 3/43 (7.0%) C: 0/39 (0%) p=0.06 No statistically significant difference between groups at 6 mos for lipids, TG, serum insulin, serum glucose, HOMA | Waist Circumference Waist Circ(cm) IG: -8.2(6.9) CG: -2.8 (5.6) p<0.001 | Any A.E.: I: 6/43 (13.9%) C: 3/39 (7.8%) NS See cardiovascular effects reported in physiological outcomes column Total rate of discontinuation due to A.E. among those taking sibutramine (I group in months 0–6 and 7–12, C group in months 7–12): 10/82 (12.2%); due to increased BP or HR 5/82 (6%), ecchymoses, VPCs or rash of unclear etiology Sexual maturity: NR Height change: NR | Good | Results of physiological, anthropometric, and adverse outcomes are reported in those columns.
Berkowitz et al 2006 Daniels et al 2007 | RCT 498 adolescents 33 weight-loss clinics USA Databases of weight-loss clinics; advertisements Weight loss July 2000–February 2002 Funding: Pharmaceutical | Age: 12–16 (Mean 13.7) 65.7% Female White: 56.6% Black: 21.1% Hispanic: 15.7% Other: 6.6% SES: NR Co-morb: 0% DM BP > 130/85 I: 5 (1.4%) C: 3 (2.3%) | 498 randomized I: 368 C: 130 Retention: I: 281 (76%) follow-up C: 80 (62%) follow-up | [underlined: Inclusion:] Age 12–16; BMI ≥ 2 SD more than U.S. weighted mean of the 95th %ile based on age/sex per 1998 Rosner norms (ref 17); BMI ≤ 44 [underlined: Exclusion:] cardiovascular disease; Type 1 or 2 diabetes; major psychiatric disorder; pregnancy; use of wt-loss medication or participation in weight loss program for >2 wks; use of medication associated with wt gain; use of medication contraindicated with use of sibutramine; cigarette smoking; SBP >130 mm HG; DBP >85 mm Hg; pulse rate > 95 beats/min | I: Sibutramine + Behavior Therapy C: Placebo + Behavior Therapy | 10 mg daily, increase to 15 mg daily at 6 mos if have not lost 10% of initial BMI or more. Total of 12 mos. At 6 mos increased to 15 mg dose N=174 (47.9%) of the Sibutramine group | BMI: I: 36.1 ± 3.8 C: 35.9 ± 4.1 NS | NA | [underlined: 12-mo] % change in BMI: I: -9.4 ± 0.51 C: -1.2 ± 0.90 p<0.001 Absolute change in BMI: I: -2.9 C:-0.3 p<0.001 (using LOCF) | NA | NA | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No [underlined: Mean difference between groups:] Systolic BP: 1.0 mm HG (95% CI 0.1 – 1.9) p=0.03 Diastolic BP: 1.7 mmHG (95% CI 1.0–2.5) p<0.001 Pulse rate: 2.5 beats per minute (95%CI 1.6–3.3) p<0.001 (For the BP parameters, the differences between groups were a reflection of a reduction in BP in the control group and slight (or no) reduction on average in the sibutramine group.) | Waist circumference WC (cm): IG: -8.2 ± 0.49 CG: -1.8 ± 0.86 p<0.001 | Any A.E.: I: 327/368 (89%) C: 111/130 (85%) NS Serious A.E.: I: 2.7% (10/368) 0.8% (1/130) p=0.30 Discontinuation due to A.E. I: 23/368 (6%) C: 7/130 (5%) p=0.83 Tachycardia: I: 46/368 (13%) C: 8/130 (6%) p=0.05 ECG: No clinically significant QTc prolongation or other mean changes from baseline. Also see additional relevant results in physiological outcomes and comments columns Growth and Maturation were not detectably different Other A.E. with >1 percentage point differences between groups (all NS.): dry mouth, constipation, dizziness | Good | I group showed more improvement than C group in: waist circumference, fasting triglycerides, HDL, fasting insulin, homeostasis model assessment of insulin sensitivity. No difference between groups for serum total cholesterol, LDL, and glucose. C group showed more improvement than I group in systolic BP, diastolic BP Withdrawals due to tachycardia I: 2.4% C: 1.5% (p=0.74) Withdrawal due to hypertension I: 5/368 (1.4%) C: 0/ 130 (0%) (difference, 1.4% (95% CI 0.4% – 3.1%)) No significant differences between groups for suicide attempts (1/368 (0.3%) in the sibutramine group vs. 1/130 (0.8%) in the CG. The two suicide attempts were considered unlikely related to the study drug, but treatment was discontinued for both patients. Reported syncope, chest pain, arrhythmia, or extra systoles was ≤ 1.5% for each in both groups.
Van Mil et al, 2007 | RCT 24 adolescents Obesity research center The Netherlands Regional public health department, pediatric outpatient clinic of teaching hospital Weight Loss Time period NR Funding NR | Age: 12–17 yrs (Mean 14.0 (calc)) 54.2% Female Race/Eth: NR SES: NR Co-morb: NR | 24 randomized Retention: I: 11/12 (91.7%) C: 9/12 (75.0%) | [underlined: Inclusion:] Age 12–18; BMI ≥ 97th %ile for age and sex; triceps skinfold thickness ≥ 97th %ile for age and sex per 1996 Dutch norms (ref 9); persisting obesity despite professionally supervised wt loss attempts. [underlined: Exclusion:] Endocrine or other secondary causes of overweight; significant physical or medical illness. | I: Sibutramine + Behavior Therapy C: Placebo + Behavior Therapy | Wks 1–2: 5 mg/day Wks 3–12: 10 mg/day | BMI: I: 30.1 ± 4.5 C: 33.3 ± 5.0 BMI SDS: I: 2.60 ± 0.55 C: 2.97 ± 0.47 | NA | NA | NA | [underlined: 6-mo (3-mo post-intervention)]: BMI change: I: -0.8 (calc) C: -1.4 (calc) (could not calculate SD) BMI SDS change: I: -0.14 (calc) C: -0.13 (calc) (could not calculate SD) Compliance NR | Lipids: No Glucose tol: No BP: Yes Phys fitness: No | Fat mass, free fat mass | Any A.E. # events/# partic I: 41/12 C: 22/12 # partic with A.E I: 12/12 (100%) C: 9/12 (75.0%) NS Abdominal complaints I: 7/12 (58.3%) C: 0/12 (0.0%) p<0.01 No differences between groups in heart rate, BP, ECG changes | Fair | No other outcomes showed significant group differences
Garcia-Morales et al, 2006 | RCT 52 adolescents Primary care pediatric obesity clinic Mexico Outpatients attending endocrinology department of children's hospital. Weight loss August 2001–August 2003 Funding: Pharmaceutical | Age: 14–18 yrs (Mean 15.0 (c)) 56.5% Female(c) Race/Eth NR SES: NR Co-morb: NR | 70 screened 52 randomized I: 26 C: 25 Drop-out before 1 mo of treatment I: 3 C: 2 Completed 6 mo I: 21 (81%) C: 19 (76%) Analyzed I: 23 C: 23 | [underlined: Inclusion:] Living in the Mexico City metropolitan area; 14–18 yrs; BMI > 95 percentile for age and sex. [underlined: Exclusion:] Lactating or pregnant females; females sexually active without contraception; SBP ≥ 140 mmHg or DBP ≥ 90 mmHg; history of anorexia nervosa or bulimia; no treatment within 30 days with corticosteroids, MAOIs, antidepressants, lithium, weight loss drugs, nasal or respiratory anticongestives, migraine treatment, gastrointestinal prokinetics, or antihistamines; using alcohol or recreational drugs; history of depression or weight loss treatment in last 6 mo; genetic disease associated with obesity; hypothyroidism; cancer; blood disease; gastrointestinal surgery; psychiatric disease; history of work or school problems; weight loss ≥ 3 kg in last 3 mo; unable to follow protocol. | I: Sibutramine + diet/exercise counseling C: Placebo + diet/exercise counseling | 10 mg/day 6 month | BMI I: 35.1 ± 5.3 C: 36.6 ± 5.2 Weight I: 92.6 ± 14.6 C: 98.9 ± 22.7 | BMI I: -3.4 (-2.5, -4.2) C: -1.8 (-0.9, -2.6) p< 0.005 (ANOVA testing interaction between treatment and time) Weight I: -7.7 (-5.2, -10.2) C: -3.8 (-1.6, -5.9) p< 0.005 (ANOVA testing interaction between treatment and time) | NA | NA | NA | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | Waist Circumference WC and % change in WC: NS between groups | Mild AE: IG: 3/23 patients (headache, dry mouth; HA w/ nausea; HA w/ weakness and paleness) CG: 3/23 patients (HA, HA w somlolence, HA w/ dry mouth) P > 0.05 between groups Withdrawl due to AE: none in either group Sexual maturity: All patients were in Tanner stage IV at baseline and end of study Height: not different between groups | Fair | No other outcomes showed significant group differences
Godoy-Matos, 2005 | RCT 60 adolescents Research setting designed to reflect clinical practice Turkey Recruitment NR Weight loss January 2002–April 2003 Funding: Pharmaceutical | Age: 14–17 yrs 82% Female Race: NR SES: NR Co-morb: None | 68 patients recruited 8 subjects were lost after run-in period 60 randomized I: 30 C: 30 Completed I: 28 C: 22 | [underlined: Inclusion:] 14–17 yrs; BMI 30–45. [underlined: Exclusion:] Diabetes mellitus; endocrine diseases predisposing to obesity; severe hyperlipidemia; systemic or major psychiatric disorders; history of bulimia or anorexia; uncontrolled hypertension (DBP > 110 mmHg) or other cardiac diseases; weight loss of 3 kg or more within 2 mo or use of weight loss/gain drugs within 3 mo; drug or alcohol abuse; recent tobacco cessation or intention to quit during study period; pregnancy or lactation. | I: Sibutramine + diet/exercise counseling C: Placebo + diet/exercise counseling | 1 mo run-in: placebo 6 mo: 10 mg/day | BMI, at wk -4 I: female 37.5 ± 3.8 male 37.6 ± 4.3 C: female 35.8 ± 4.2 male 37.4 ± 1.9 NS Weight, kg at wk 0 I: female 97.7 ± 14.9 male 115.2 ± 14.7 C: female 91.9 ± 13.1 male 110.2 ± 8.8 NS | BMI change I: -3.6 ± 2.5 C: -0.9 ± 0.9 p<0.001 Weight loss, kg I: -10.3 ± 6.6 C: -2.4 ± 2.5 p<0.001 | NA | NA | NA | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | Waist Circumference; waist to hip ratio | Constipation I: 40% C: 13.3% p=0.039 All others NS: dry mouth, heache, constipation, abdominal pain, cold dizzy. No one withdrew due to AE | Fair
| Orlistat
Chanoine et al, 2005 | RCT 539 adolescents 32 institutions with established pediatric obesity treatment programs Canada and USA Advertisements in participant clinics and media, referrals from family physicians Weight loss August 2000–October 2002 Funding: Pharmaceutical | Age: 12–16 (Mean 13.6 (c)) 67% Female (c) 76.0% White (c) 16.9% Black (c) 7.1% Other (c) SES: NR 25.3% metabolic syndrome 1% DM | 588 Evaluated 49 Excluded (did not meet incl crit (42), other (7)) 539 Randomized I: 357 C: 182 Retention: I: 232/257 (65.0%) C: 117/180 (64.3%) | [underlined: Inclusion:] Age 12–16; BMI ≥ 2 SD more than U.S. weighted mean of the 95th %ile based on age/sex per Rosner 1998 norms (ref 1); parent/guardian willing to attend study visits with them; willing to be actively involved in behavioral modification [underlined: Exclusion:] BMI ≥ 44; body wt ≥ 130 kg or <55 kg; wt loss of ≥ 3 kg in past 3 mos; diabetes requiring antidiabetic meds; obesity associated with genetic disorders; psychiatric disorder; use of dexamphetamine or methylphenidate; active GI tract disorder; bulimia or laxative abuse; use of anorexiants or weight-loss treatment in past 3 mos | I: Orlistat + Behavior Therapy C: Placebo + Behavior Therapy | Wks 1–2: placebo Wks 3–54: 360 mg/day Compliance I: 73% C:72% | BMI: I: 35.7 ± 4.2 C: 35.4 ± 4.1 | NA | [underlined: 12-mo:] Adjusted Mean change in BMI: I: -0.55 C: +0.31 p<.001 | NA | NA | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | Waist & Hip Circumference, fat mass | Any A.E. I: 97% C: 94% Serious A.E. I: 11/352 (3.1%) C: 5/181 (2.8%) discontinued tx due to A.E.: I: 12/352 (3.4%) C: 3/181 (1.7%) Also assessed and found no group differences: levels of vit. A, D, E, & beta carotene; levels of estradiol; change in height; sexual maturation, bone mineral density | Good | I group showed greater improvements than C group in waist circumference, hip circumference, fat mass, and diastolic BP
Maahs et al 2006 | RCT 40 adolescents Research clinic USA Physician referal and newpaper advertisement Weight loss December 2002–February 2003 Funding: University supported | Age: 14–18 (Mean 15.8) 67.5% Female(c) 62.5% Hispanic (c) SES: NR Co-morb: NR | 43 evaluated 3 excluded (parent refusal, not interested, psychological issues) 40 randomized I: 20 C: 20 Retention: I: 16/20 (80%) C: 18/20 (90%) p=0.68 | [underlined: Inclusion:] Age 14–18; BMI >85th %ile of age and sex (norms NR) [underlined: Exclusion:] known secondary cause for obesity (e.g., hypothyroidism, daily corticosteroid exposure, genetic disorder); pregnancy | I: Orlistat + monthly diet/exercise counseling C: Placebo + monthly diet/exercise counseling | 360 mg/day, 6 mos | BMI: I: 39.2 ± 1.2 C: 41.7 ± 2.6 Weight I: 111.1 ± 5.1 C: 114.3 ± 8.6 | [underlined: 6-mo:] BMI: I: 37.9 ± 1.6 C: 40.9 ± 3.0 p=0.70, for time-by-group effect (including 3-mo values) Weight I: 105.6 ± 6.2 C: 112.7 ± 9.5 p=0.76 | NA | NA | NA | Lipids: Yes Glucose tol: Yes BP: No Phys fitness: No | % body fat by bioelectrical impedance analysis | Discontinue due to A.E.: I: 2/20 (10%) C: 0/20 (0%) p-value NR I group reported higher levels of: soft stools (p=0.002); oily spotting (p<0.001); fatty or oily stools (p<0.001); oily evacuation (p<0.001); liquid stools (p=0.02); cramping (p=0.02); flatus w discharge (p<0.001); fecal incontinence (p<0.001) | Fair | No other outcomes listed here showed significant group differences
| Metformin-in special population
Srinivasan et al, 2006 | Cross-over RCT 28 children and adolescents Pediatric endocrine clinic Australia Physician referal to endocrine clinic of pediatric hospital Change in body composition March 2002–March 2003 Funding: Research scholarship and grant | Age: 9–18 (Mean 12.5) 53.6% Female (c) 64% Pacific Islands or Indian subcontinent 25% Northern European 11% Mixed heritage SES: NR Co-morb: 0% DM | 34 assessed for eligibility 28 randomized: Group A (metformin first): 13 Group B (placebo first): 15 Retention: A: 10/13 (76.9%) B: 12/15 (80.0%) follow-up | [underlined: Inclusion:] Age 9–18; referred to endocrine clinic with obesity per International Obesity Task Force definition; clinical suspicion of insulin resistance as defined by either a fasting insuline to glucose ratio >4.5 OR the presence of acanthosis nigricans. [underlined: Exclusion:] Known type 1 or 2 DM; contraindications to metformin; contraindications to MRI; weight >120 kg | A: Metformin, then placebo B: Placebo, then metformin | 6 months metformin, gradually increased (over 3 wks) up to 2 g/day, 6 months placebo Compliance I: 78% (15–99%) C: 78% (35–98%) p=0.689 | BMI, overall: 35.2 ± 5.1 BMI SDS, overall: 2.43 ± 0.28 Weight, kg, overall: 89.9 ± 17.6 | Metformin treatment effect size: Weight, kg: -4.35 p=0.02 BMI -1.26 p=0.002 BMI SDS: -0.12 p=0.005 | | | | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | Waist circumference, subcutaneous abdominal adipose tissue, visceral abdomnial adipose tissue, % total body fat. | Any A.E. 2/28 (7%) nausea prevented full dose (both 9-year-olds, youngest age in study) They tolerated 750 mg ×2/day Serious A.E. 0/28 (0%) Discontinued treatment due to A.E.: NR | Fair | Fasting insulin and fasting glucose improved with metformin use; sc abdominal adipose tissue reduced with metformin use.
Freemark et al., 2001 | RCT 32 adolescents University research clinic USA Recruitment strategy: NR Funding: Pharmaceutical and General Clinical Research Center Grant | Age: 12 – 19 years (Mean for CG: 15.4 ± 0.5; IG: 14.4 ± 0.6) 62% Female (c*) 55%White(calc*) 45% Black (calc*) SES: NR % Co-morbid:NR 8 pts had acanthosis nigricans (all were black) *=data were reported only for 29/32 who completed trial | #assessed for eligibility: NR 32 randomized I: 15 C: 17 %retention: I: 93% C: 88% analyzed completers only | Inclusion: Age 12 – 19 who had reached Tanner stage III puberty; BMI > 30 kg/m2; fasting insulin concentration > 15 μU/mL; at least 1 first- or second-degree relative with type 2 diabetes; normal fasting glucose concentration (< 110 mg%) and HbA1c concentration (≤ 6.0%). Exclusion: NR | IG: Metformin CG: Placebo No attempt was made to control the caloric intake or food selection of the patients | Metformin 500 mg or Placebo, twice per day (1 at breakfast; 1 at dinner) × 6 months | BMI: IG: 41.5 ± 0.9 CG: 38.7 ± 1.3 (p < 0.05) | [underlined: 6 mos:] BMI SDS IG: -0.12 CG: 0.23 p< 0.02 BMI IG: -0.5 kg/m2 CG: 0.9 kg/m2 p-value NR | N/A | N/A | N/A | Glucose tol=yes lipids=yes | No | No patients discontinued due to adverse events; no episodes of vomiting or lactic acidosis; serum lactate, liver and renal function parameters remained normal IG: 1 pt intermittent nausea in mos 3–4 until metforming dose was reduced by 50%; 3 abdominal discomfort during first 1–2 wks CG: 1 had abdominal discomfort | Fair | Fasting glucose improved more in IG than CG (p<0.01); No other statistically significant differences between groups for insulin levels or various measures of insulin sensitivity; nodifference in serum lipids between groups

Evidence Table 4. Surgical intervention trials

Study Reference | Country Setting Recruitment Source Years | Surgical Encounter Characteristics | Inclusion/Exclusion | Patient Characteristics (% with DM, IGT, hypertension, hyperlipidemia) | Duration of follow-up | Mean Entry Weight | Change in Weight | Resolution of co-morbidities post surgery | Other positive outcomes | Adverse effects | Study Quality
Laproscopic adjustable gastric banding trials
Abu-Abeid 2003 | Israel Multidisciplinary obesity center with pre-operative evaluation and post-surgical follow-up Patients were referred after failing diet management through dietician. Years NR | Laparoscopic adjustable gastric banding (Lap-Band^®^) Surgeon characteristics NR Procedure time: NR Hospital stay: 24 hours (1 patient 48 hours) | Inclusion: Fulfilled the NIH criteria for morbid obesity; failed weight reduction after 1 yr under supervision of a dietician. Exclusion: NR | N: 11 Age: 15.7 y (11–17) Female: 72.7% Race/Eth: NR SES: NR Co-morbidities Heart failure and pulmonary hypertension: 9% (1/11) Amenorrhea: 18% (2/11) Gallstones: 9% (1/11) High triglycerides: 18% (2/11) Abnormal cholesterol: 9% (1/11) | 23 mo (6–36) n=11/11 | BMI: 46.6 kg/m^2^ (38–56.6) | Mean decrease in BMI (calculated): 14.5 kg/m^2^ Mean BMI at follow-up: 32.1 kg/m^2^ | Amenorrhea: 100% High triglycerides: 100% (2/2) Abnormal cholesterol: 0% (0/1) | None | Perioperative complications: 0% Late complications: 0% | Fair/poor Data collection: NR
Angrisani 2005 | Italy Cases were collected from the electronic database of the Italian Collaborative Study Group for Lap-Band. Multidisciplinary team completed pre-operative evaluation. January 1996–December 2003 | Laparoscopic adjustable gastric banding (Brand NR) Surgeon characteristics NR Procedure time: NR Hospital stay: NR | Inclusion: ≤ 19 yrs; BMI ≥ 40 or ≥ 35 with comorbities; supportive family environment; failure to obtain weight loss after ≥ 1 yr of conservative medical treatment; psychologic maturity with decisional capacity; willingness to be operated on and follow post-op guidelines. Exclusion: Psychiatric or genetic disorders. | N: 58 Age: 17.96 ± 0.99 y Female: 81% Race/Eth: NR SES: NR Co-morbidities Any co-morbidty: 46.5% (27/58) Anxiety/depression: 19% (11/58) Hypertension: 14% (8/58) Dyslipidemia: 10% (6/58) Diabetes: 14% (8/58) Osteoarthropathy: 21% (12/58) Sleep apnea: 17% (10/58) Amenorrhea: 7% (4/58) | Range 0–7 yrs 1 yr: 48/52 (92.3%) 3 yr: 37/42 (88.1%) 5 yr: 25/33 (75.7%) 7 yr: 10/10 (100%) | BMI: 46.1 ± 6.31 kg/m^2^ 16% had BMI ≥ 50 kg/m^2^ | Mean decrease in BMI (calculated): 1 yr Completed: 10.2 kg/m^2^ Intention-to-treat (ITT): 9.4 kg/m^2^ 3 yr Completed: 8.3 kg/m^2^ ITT: 7.3 kg/m^2^ 5 yr Completed: 11.2 kg/m^2^ ITT: 8.5 kg/m^2^ 7 yr Completed: 16.4 kg/m^2^ ITT: 16.4 kg/m^2^ Failures: ≤ 25% EWL at 5 yrs: 20% (5/25) | NR | None | Mortality: None Laparotomic conversion: 1.7% (1/58) Overall postoperative complications: 10.3% (6/58) Band slip: 1.7% (1/58) Gastric pouch dilation: 3.4% (2/58) Intragastric migration: 5.2% (3/58) Band removal: 10.3% (6/58) Conversion to gastric bypass or BPD: 5.2% (3/58) | Fair Small numbers, one with Prader-Willi syndrome; Data collection: Retrospective review of electronic database of the Italian Collaborative Study Group for Lap-Band.
Dolan 2003 Dolan 2004 Fielding 2005 | Australia Surgical department, community hospital. Multi-disciiplinary team completed pre-operative evaluation. Recruitment source NR Years NR | Laparoscopic adjustable gastric banding (Lap-Band^®^) Single surgeon Procedure time: NR Hospital stay: NR | Inclusion: < 20 yrs, other criteria NR Exclusion: NR | N: 17 Age: Median 17 (12–19) Female: 82.4% Race/Eth: NR SES: NR Co-morbidities: NR | Median 25 mo (12–46) [underlined: Follow-up] 12 mo: 17/17 24 mo: 11/17 | BMI (calculated): 43.1 kg/m^2^ (30.3–70.5) Weight (calculated): 129.19 kg (82.9–218.8) | Mean decrease in BMI (calculated) 12 mo: 10.1 kg/m^2^ 24 mo: Reported 12.7 kg/m^2^ ITT 8.2 kg/m^2^ Mean decrease in weight (calculated) 12 mo: 29.9 kg 24 mo: Reported 38.7 kg ITT 25.0 kg BMI < 35: 76.5% at 12 mo; 81.8% at 24 mo | NR | None | Band slip: 5.9% (1/17) Leaking port: 5.9% (1/17) | Fair/poor Small numbers; inclusion/exclusion criteria not stated Data collection: Prospective
Nadler 2007 | NY University center with comprehensive bariatric surgery program Recruitment NR September 2001–February 2006 | Laparoscopic adjustable gastric banding (Lap-Band^®^) 3 surgeons Procedure time: 38 ± 20 min (19–134) Hospital stay: 24 hrs | Inclusion: Met NIH criteria for bariatric surgery Exclusion: NR | N: 53 Age: 15.9 y (13–17) Female: 77.4% Race/Eth: African American 6%; Hispanic 13%; White 81% SES: NR Co-morbidities: NR | Up to 24 mo Results available for 33/53 (62%) at 6 mo | BMI: 47.6 ± 6.7 kg/m^2^ Weight: 297 ± 53 lbs | Mean decrease in BMI (calculated): Completed follow-up 8.1 kg/m^2^ ITT 5.0 kg/m^2^ | NR | None | Perforated appendicitis within 10 days of surgery: (1.9% 1/53) Band slip 3.8% (2/53) Hiatal hernia 3.8% (2/53) Wound infection 1.9% (1/53) Mild hair loss 9.4% (5/53) Iron deficiency 7.5% (4/53) Nephrolithiasis, cholelithiasis 1.9% (1/53) Gastroesophageal reflux 1.9% (1/53) | Fair Clearly stated “all” adolescents Data collection: All patients prospectively entered into database.
Silberhumer 2006 Widhalm 2004 | Austria 3 bariatric surgery centers, Multi-disciplinary team support before and after surgery Referral source NR Years 1998-2004 | Laparoscopic adjustable gastric banding ((Lap-Band^®^ n=13; SAGB^®^ n=37) Multiple surgeons Procedure time: 55 ± 35.5 min Hospital stay: 4.0 ± 4.4 days | Inclusion: Unsuccessful weight loss through behavioral or drug therapy; above 99.5th percentile for age and gender; those < 14 yrs also had to have at least one co-morbidity. Exclusion: NR | N: 50 Age: 17.1 yrs (9–19) Female: 62% Race/Eth: NR SES: NR Co-morbidities Atleast 1 co-morbidty 62% DM II: 10% (5/50) Hypertension: 24% (12/50) Dyslipidemia: 8% (4/50) Asthma: 6% (3/50) Cholecystolithiasis: 6% (3/50) | Mean follow-up: 34.7 ± 17.5 mo. (3.6–85.4) n=50/50 | BMI: 45.2 kg/m^2^(32.5–76.7) | Mean decrease in BMI (calc): 12.6 kg/m^2^ Mean decrease in weight: 35.2 ± 23.0 kg (4–120 kg) Failures: 6% (3/50) had EWL < 25% after at least 1 yr of follow-up | Resolution DM II: 80% (4/5) Hypertension: 50% (6/12) Dyslipidemia: 100% (4/4) Asthma: 100% (3/3) Cholecystolithiasis: 100% (3/3) | At last follow-up QOL (Moorehead-Ardelt): 0.8 ± 03 to 2.1 ± 0.8 Body image-BAROS: significantly improved Agility-BAROS: increased Psychosocial outcome-BAROS: Excellent 24% (12/50) Very good 40% (20/50) Good 24% (12/50) Fair 10% 5/50) Failure 2% (1/50) | Perioperative complications: 0% Dislocated port: 2% (1/50) Band slip: None | Fair Data collection: Clinic follow-up
Yitzhak 2006 | Israel Surgical department of university hospital. Psychological assessment prior to surgery. Recruitment NR 2000-2006 | Laparoscopic adjustable gastric banding (SAGB^®^) Single surgeon Procedure time: NR Hospital stay: NR | Inclusion: ≤ 18 yrs; NIH criteria for bariatric surgery; failed conservative weight loss methods. Exclusion: NR | N: 117 total; n= 60 ≥ 36 mo follow-up Age: 16 (9–18) Female: 70% Race/Eth: NR SES: NR Co-morbidities Any co-morbidity: 23% Hypertension: 5% Diabetes: 3.3% Asthma: 5% Sleep apnea: 16.7% | Mean follow-up for those with ≥ 36 mo: 39.5 mo n=60/60 | BMI: 43 kg/m^2^ (35–61) | Self-reported measures-Not used | 100% resolution of all co-morbidities. Hypertension: 3/3 Diabetes Mellitus: 2/2 Asthma: 3/3 Obstructive sleep apnea: 10/10 | Improvement in physical activity: 93% (56/60) Improvement in social self-esteem 72% (43/60) Would you undergo the operation again? Yes-93% (56/60) | Mortality: 0% Major post-operative complications: 0% Band slip: 10% (6/60) Band removal: 3.3% (2/60) | Fair/poor Data collection: Review of medical and clinic records; telephone questionnaire.
Gastric Bypass Trials
Lawson 2006 | Multi-site US 3 pediatric surgical centers Recruitment NR May 2001–October 2003 | Laparoscopic Roux-En-Y Gastric Bypass (n=3 open procedure) Surgeons at 3 centers Procedure time: NR Hospital stay: NR | Inclusion: BMI ≥ 40 kg/m^2^ with serious comorbidities or BMI ≥ 50 kg/m^2^ with less severe comorbidities; unsuccessful medical weight loss previously. Exclusion: NR | N: n=30 weight n=36 harms Age: Mean NR (13–21) Female: NR Race/Eth: NR SES: NR Co-morbidities: NR | 12 mo (10–14) n=30 Harms data reported for patients that were not seen in the 10–14 mo window. N=36 | BMI: 56.5 ± 5.2 kg/m^2^ (41.9–95.5) | Mean decrease in BMI: 20.7 ± 8.1 kg/m^2^ (3.3–43.5) Failures: 6.7% (2/30) in 1st year regained weight-up to 50% of weight lost. All patients were still overweight to severe obesity at 1 yr follow-up. | NR | 1 successful and healthy pregnancy within the 1st year. | 2/36 were converted to an open procedure (5.6%) Minor complications (readmission < 7 days): 9/36 (25%) Moderate complications (readmission or sequelae for 7–30 days): 4/36 (11%) Severe complication (sequelae for more than 30 days): 2/36 (5.6%), which includes 1 death 9 months post-operative due to complications from severe infectious colitis. Non-compliant with 12 mo. office visit: 23% (9/39) | Fair Patient population not well described. Data collection: retrospective medical record review. Loss to follow-up with physician: 8% (3/36)
Collins 2007 Stanford 2003 | Pennsylvania Hospital surgical center with multidisciplinary specialists from affiliated Children's Hospital evaluating before and after surgery. Recruitment NR Years NR | Laparoscopic Roux-En-Y Gastric Bypass Surgeons NR Procedure time: NR Hospital stay: Mean 2.1 days | Inclusion: BMI ≥ 35 kg/m^2^ with comorbid conditions or ≥ 40 kg/m^2^ without comorbid conditions who have failed attempts at traditional methods of weight loss. Carefully selected after multi-disciplinary evaluation of patient with families. Exclusion: NR | N: 11 Age: 16.5 ± 0.2 yrs (15–18) Female: NR Race/Eth: NR SES: NR Co-morbidities Diabetes: 54.5% (6/11) Hypertension: 54.5% (6/11) Sleep apnea: 18.2% (2/11) Hypercholesterolemia: 45.5% (5/11) Hypercholesterolemia: 18.2% (2/11) Fatty liver/steatosis: 45.5% (5/11) Polycystic ovarian syndrome: 27.3% (3/11) | Mean 11.5 ± 2.8 mo (3–32) n=11/11 < 6 mo 6/11 | BMI: 50.5 ± 2.0 kg/m^2^ (42–66) Weight: 329.7 ± 15.7 lbs (242–418) | No valid reported outcomes available. | Diabetes: 50% (3/6) Hypertension: 50% (3/6) Obstructive sleep apnea: 100% (2/2) no longer required constant positive airway pressure at night Polycystic ovarian syndrome: 67% (2/3) All co-morbidities: 30.1% resolved. | All patients described self-esteem, physical function, social interactions, and function at work as either “improved” or “greatly improved” | Postoperative bleeding: 3/11 (27.3%) with 1 of these needing laporoscopic reevaluation. Marginal ulcer: 2/11 (18.2%) (1 and 18 mo postoperative) Non-compliant with vitamin regimen: 18.2% (2/11) | Fair/poor Data collection: Retrospective medical chart review.
Soper 1975 Anderson 1980 | USA-Iowa Pediatric surgery department of university hospital Recruitment NR 1969-1973 | Open gastric bypass (n=NR); Horizontal gastroplasty (n=NR) Multiple surgeons at single center Procedure time: NR Hospital stay: NR | Inclusion: Twice ideal body weight; good health except for obesity-related disorders; potential for normal physical activity; endocrine disorder not cause of obesity. Exclusion: NR | N: 18 Age: Median 19 (≤ 20 yrs) Female: 55.6% Race/Eth: NR SES: NR Co-morbidities: NR | 6 mo: 94.4% (17/18 estimated) 10–15 mo: 77.8% (14/18 estimated) | Median weight: 147.0 kg | Median weight loss, % body weight: 6 mo: Reported 15% ITT 14.2% 10–15 mo: Reported 30% ITT 23.3% | NR | None | Revision: 5.6% (1/18) Wound infection: 12% (3/25*) Respiratory difficulty: 12% (3/25*) Thrombophlebitis: 4% (1/25*) Upper gastrointestinal bleed: 4% (1/25*) Urinary tract infection: 4% (1/25*) Protracted vomiting: 4%(1/25*) Incisional hernia: 16% (4/25*) *n=25, which includes 7 Prader-Willi patients | Fair/poor Data collection: NR
Sugerman 2003 | USA-Virginia Surgical department of university hospital Recruitment NR 1981– January 2002 | Laparoscopic gastric bypass (n=2); Open gastric bypass (n=15); Long-limb gastric bypass (n=10); Distal gastric bypass (n=3); Horizontal gastroplasty (n=1); Vertical banded gastroplasties (n=2) Surgeon characteristics NR Procedure time: NR Hospital stay: NR | Inclusion: 12 to < 18 yrs; eligible for bariatric surgery according to the NIH adult criteria. Exclusion: NR | N: 33 Age: 16 ± 1 yr (12.4–17.9) Female: 57.6% Race/Eth: White 81.8%; Black 18.2% SES: NR Co-morbidities Diabetes Mellitus II 3% (1/33) Hypertension 30.3% (10/33) Pseudotumor cerebri 6.1% (2/33) Sleep apnea 18.2% (6/33) | 1 yr n=31/32 5 yr n=20/24 10 yr n=14/18 14 yr n=6/9 | BMI: 52 ± 11 kg/m^2^ (38–91) Weight: 150 ± 40 kg (100–303) | Mean decrease in BMI 1 yr: Reported 16 kg/m^2^ (calc) ITT 15.5 kg/m^2^ (calc) 5 yr: Reported 19 kg/m^2^ (calc) ITT 15.8 kg/m^2^ (calc) 10 yr: Reported 18 kg/m^2^ (calc) ITT 14 kg/m^2^ (calc) 14 yr: Reported 14 kg/m^2^ (calc) ITT 9.3kg/m^2^ (calc) Failures: 15% (5/33) regained all or most of weight lost at 5–10yrs | Diabetes Mellitus II 100% (1/1) Hypertension 80% (8/10) Sleep apnea 100% (6/6) | None | Late complications: 21% (7/33) Incisional hernia: 18.2% (6/33) Bowel obstruction: 3% (1/33) Conversions to another type of bypass due to late weight gain or severe protein-calorie malnutrition: 6% (2/33) Early complications: Pulmonary embolism 3% (1/33) Major wound infection 3% (1/33) Minor wound infection 12% (4/33) Stomal stenoses 9% (3/33) Marginal ulcers 12% (4/33) No patients had evidence of impaired sexual or physical maturation. | Fair Data collection: Retrospective medical record review.
Capella 2003 | USA-New Jersey University Medical Center Recruitment NR May 1990–August 2001 | Vertical banded gastroplasty-Roux-en-Y gastric bypass-open procedure Surgeon information NR Procedure time: NR Hospital stay: NR | Inclusion: NR Exclusion: NR | N: 19 Age: 15.6 yrs (calc)(13–17) Female: NR Race/Eth: NR SES: NR Co-morbidities Dyslipidemia: 15.8% (3/19) Sleep apnea: 15.8% (3/19) Pulmonary hypertension 5.3% (1/19) Hypertension: 15.8% (3/19) Liver steatosis: 21% (4/19) Diabetes: 10.5% (2/19) Peptic esophagitis: 15.8% (3/19) Cholelithiasis: 10.5% (2/19) | Mean 5.5 yrs (1–10) (n=19/19) | BMI: 49 kg/m^2^ (38–67) Weight: 133 kg (91–201) | Mean decrease in BMI: 19 kg/m^2^ | NR | None | Mortality: None Revisions: 10.5% (2/19) Cholecystectomy: 5.3% (1/19) | Fair Data collection: “contact with patients was made through office visits, their personal physicians and by phone or mail.”
Strauss 2001 | USA-New Jersey University Hospital Identified in database of those undergoing bariatric surgery at Medical School. Three patients without co-morbidities had psychological evaluation prior to surgery. April 1985– May 1999 | Open Roux-en-Y gastric bypass Single surgeon Procedure time: NR Hospital stay: NR | Inclusion: Developmentally and genetically normal; > 100% above ideal body weight; at least 100 lbs over ideal body weight; previously unsuccessful at weight loss, typically for > 3 yrs. Exclusion: NR | N: 10 Age: (15–17) Female: 70% Race/Eth: NR SES: NR Co-morbidities Hypertension: 30% (3/10) Sleep Apnea: 20% (2/10) | Mean 5.75 yrs (0.67–13 yr) (n=10/10) > 1 yr in 90 % (9/10) | Weight: 148 ± 37 kg BMI: 52.4 kg/m^2^ (calc) | Mean decrease in weight: 46.8 kg (calc) Satisfactory weight loss in 90% (9/10) Failures: 3 women who became pregnant regained 13–45 kg | NR | Three uneventful pregnancies occurred. | Protein-calorie malnutrition/micronutrient deficiency: 10% (1/10) Cholecystectomy: 20% (2/10) Small bowel obstruction 10 yrs postoperative: 10% (1/10) Incisional hernia: 10% (1/10) | Poor Data collection: Medical record review on 5 patients; Self-report weight was by phone interview in 4 patients. 1 patient was lost-to-follow-up.
Barnett 2005 | USA-Minnesota Department of surgery-university hospital Recruitment 1971-2001 | Open Roux-en-Y gastric bypass (n=5); Vertical banded gastroplasty (n=7); Jejunoileal bypass (n=3) Single surgeon Procedure time: NR Hospital stay: Mean 7 days (4–11) | Inclusion: NIH criteria for bariatric surgery Exclusion: NR | N: 14 Age: 15.7 yrs (13–17) Female: 57% Race/Eth: NR SES: NR Co-morbidities Hypertension: 35.7% (5/14) Asthma: 21.4% (3/14) Sleep apnea 14.3% (2/14) Diabetes 7.1% (1/14) Hypothyroidism 7.1% (1/14) | 9/14 had follow-up > 9 mo (9 mo to 22 yrs) | BMI: 55.1 ± 14.8 kg/m^2^ | Mean decrease in BMI: Reported: 24 ± 13.8 kg/m^2^ ITT: 15.4 kg/m^2^ (calc) > 50% EWL with > 9 mo follow-up: 77.8% (7/9) | Hypertension: 100% (5/5) Asthma: 66.7% (2/3) Sleep apnea 100% (2/2) Diabetes 100% (1/1) Hypothyroidism 0% (0/1) | All patients contacted by phone rated their experience as excellent. | Mortality: None Dumping syndrome: 14.3% (2/14) Surgical site infection: 7.1% (1/14) Hypoglycemia: 7.1% (1/14) | Fair/poor Data collection: Retrospective medical record review of patients in clinical bariatric surgery database.
Breaux 1995 | USA-Alabama Surgical unit in community hospital Recruitment NR 1983-1995 | Roux-en-Y gastric bypass (n=14); Vertical banded gastroplasty (n=5); Biliopancreatic diversion (n=4) Single surgeon Procedure time: NR Hospital stay: Mean 4.6 (4–5) days non-sleep apnea patients; 6.3 (4–22) days with sleep apnea | Inclusion: NR Exclusion: NR | N: 22 Age: 15.3 yr (calc)(8–18) Female: 59% (calc) Race/Eth: NR SES: NR Co-morbidities Sleep apnea: 50% (11/22) | Without Sleep apnea Mean 50 mo (6–131); 100% follow-up (11/11) Sleep apnea Mean 32 mo (9–105) ; 81.8% (9/11) | BMI: Without sleep apnea 56.4 kg/m^2^ Sleep apnea 67.8 kg/m^2^ Weight: Without sleep apnea 148.6 kg Sleep apnea 169 kg | Mean decrease in BMI Without sleep apnea: 20.9 kg/m^2^ (calc) Sleep apnea: Reported 23.8 kg/m^2^ (calc) ITT 19.5 kg/m^2^ (calc) Mean decrease in Weight Without sleep apnea: 52 kg (calc) Sleep apnea: Reported 74 kg (calc) ITT 60.5 kg (calc) | Sleep apnea: 100% (11/11) | None | Mortality: 2 deaths at 15 mo and 3.5 yrs postoperative. 1 had brain tumor and was admitted with protein malnutrition and a seizure disorder. She developed multisystem organ failure and family refused autopsy. The second did not have autopsy but cause of death was listed as “complications arising out of morbid obesity.” Incisional hernia: 5% (1/22) Postoperative laryngeal edema: 5% (1/22) Gallstones: 5% (1/22) Kidney stones: 5% (1/22) Nutritional deficiences: 23% (5/22) Revision: 4.5% (1/22) | Fair Data collection: NR
Rand 1994 | USA-Florida Community hospital Recruitment NR January 1979–December 1990 | Open Roux-en-Y gastric bypass (n=30); Vertical banded gastroplasty (n=4) Single surgeon Procedure time: NR Hospital stay: 5 or 6 days | Inclusion: NR Exclusion: NR | N: 34 of 39 possible Age: 17 ± 2 yrs (11–19) Female: 79% Race/Eth: NR SES: NR Co-morbidities: NR | Mean 6 yrs (2–13) (n=34/34) | BMI: 47 ± 7 kg/m^2^ Weight: 131 ± 26 kg (96–189) | Self-reported measures-Not used | NR | 85% said they would definitely elect to do surgery if they had it to do over again. | 2 cholecystectomies 1 abdominal panniculectomy No other AE reported. 3 had surgical revisions-2 were scheduled for revisions. | Fair/poor
Mason 1995 | USA-Iowa Surgical department of university hospital Recruitment NR 1980-1994 | Vertical banded gastroplasty Multiple surgeons Procedure time: Hospital stay: Mean 5.6 days-males; 5.1 days-females. | Inclusion: 14 yrs to < 21 yrs; other criteria NR. Exclusion: NR | N: 47 (2 with Prader Willi) Age: 18.1 ± 1.84 Female: 68% Race/Eth: NR SES: NR Co-morbidities: NR | At 5 yrs, data was available for 25/35 patients (71.4%). At 10 yrs, data was available for 14/19 patients (73.7%). | BMI: 48.4 kg/m^2^ Weight: 138.7 kg | Mean decrease in BMI: 5 yr Reported: 12.2 kg/m^2^ (calc) ITT: 8.7 kg/m^2^ (calc) 10yr Reported : 9.2 kg/m^2^ (calc) ITT: 6.8 kg/m^2^ (calc) ≥ 25% EWL and no revision: At 5 yrs 74% At last follow-up 61% | NR | None | Mortality: None Revisions: 8.5% (4/47) | Fair/poor Data collection: Medical record review, physician letters, self-report.
Papadia 2007 | Italy Surgical department of university hospital Recruitment NR May 1976–December 2005 | Biliopancreatic diversion Surgeon characteristics Procedure time: NR Hospital stay: NR | Inclusion: <18 yrs Exclusion: Prader-Willi syndrome; Turner syndrome. | N: 68 Age: 16.8 yrs Female: 76.5% Race/Eth: NR SES: NR Co-morbidities Hypertensive: 49% (33/68) Dyslipidemic: 16% (11/68) Hyperglycemic: 4% (3/68) Diabetes mellitus II: 3% (2/68) | Mean follow up: 11 yrs (2–23) 98.5% (67/68) | BMI: 46 kg/m^2^ Weight: 125 kg | Mean percentage of excess weight lost at last follow-up: 78% | Hypertensive: 92% (27/33) Dyslipidemic: 100% (11/11) Hyperglycemic: NR Diabetes mellitus II: 100% (2/2) | 18 women had 28 healthy pregnancies; 3 women had complicated pregnancies. | Reoperations: 19 in 14 patients (14/68=21%) Mortality long-term: 4.4% (3/68) Protein malnutriiton 1–10 yrs post surgery: 16% (11/68) Immediate complication: 1.5% (1/68) | Fair Data collection: Retrospective medical record review
Tsai 2007 | USA Healthcare Cost and Utilization Project Nationwide Inpatient Sample Sample contains a representative 20% sample of US community hospitals 1996-2003 | Procedures coded as gastric bypass (90%) or gastroplasty (10%) Surgeon characteristics NR Hospital stay: Mean in 2003 of 3.1 ± 0.2 days | Inclusion: 10–19 yrs; ICD9 code for obesity and procedure code for gastric bypass or gastroplasty. Exclusion: Diagnosis code for abdominal tumors. | N: 566 procedures Age: 12–19 yrs (96.4% were 15–19) Female: 78.6% Race/Eth: NR SES: NR Co-morbidities: NR | Length of hospital stay post surgery which was 4.1 ± 0.2 days in 1996 and declined to 3.1 ± 0.2 in 2003 p<0.001 | NA | NA | NA | None | Mortality: none Major complications: 5.5% 78.3% (119/152) of major complications were respiratory | Fair Laparoscopic procedures became increasingly used throughout the study period. Did not capture any longer-term adverse events Data collection: Inhospital experience use medical record diagnostic codes.

NIH criteria for bariatric surgery: BMI ≥ 40 or 35–40 BMI with high-risk co-morbidities.

BAROS: Bariatric Analysis and Reporting Outcome System

NR-not reported

## References for Evidence Tables

1 Abu-Abeid S, Gavert N, Klausner JM, Szold A. Bariatric surgery in adolescence. J Pediatr Surg. 2003;38:1379-1382. [pmid: 14523824].
2 Anderson AE, Soper RT, Scott DH. Gastric bypass for morbid obesity in children and adolescents. J Pediatr Surg. 1980;15:876-881. [pmid: 7463289].
3 Angrisani L, Favretti F, Furbetta F, et al. Obese teenagers treated by Lap-Band System: The Italian experience. Surgery. 2005;138:877-881. [pmid: 16291388].
4 Barnett SJ, Stanley C, Hanlon M, et al. Long-term follow-up and the role of surgery in adolescents with morbid obesity. Surgery for Obesity & Related Diseases. 2005;1(4):394-8. Aug. [pmid: 16925256].
5 Berkowitz RI, Fujioka K, Daniels SR, et al. Effects of sibutramine treatment in obese adolescents: A randomized trial. Ann Intern Med. 2006;145:81-90. [pmid: 16847290].
6 Berkowitz RI, Wadden TA, Tershakovec AM, Cronquist JL. Behavior therapy and sibutramine for the treatment of adolescent obesity: A randomized controlled trial. JAMA. 2003;289:1805-1812. [pmid: 12684359].
7 Braet C, Tanghe A, Bode PD, Franckx H, Winckel MV. Inpatient treatment of obese children: A multicomponent programme without stringent calorie restriction. Eur J Pediatr. 2003;162:391-396. [pmid: 12756560].
8 Breaux CW. Obesity surgery in children. Obes Surg. 1995;5:279-284. [pmid: 10733812].
9 Budd GM, Hayman LL, Crump E, et al. Weight loss in obese African American and Caucasian adolescents: Secondary analysis of a randomized clinical trial of behavioral therapy plus sibutramine. J Cardiovasc Nurs. 2007;22:288-296. [pmid: 17589281].
10 Capella JF, Capella RF. Bariatric surgery in adolescence. Is this the best age to operate?. Obes Surg. 2003;13:826-832. [pmid: 14738664].
11 Carrel AL, Clark RR, Peterson S, Eickhoff J, Allen DB. School-based fitness changes are lost during the summer vacation. Archives of Pediatrics & Adolescent Medicine. 2007;161:561-564. [pmid: 17548760].
12 Carrel AL, Clark RR, Peterson SE, Nemeth BA, Sullivan J, Allen DB. Improvement of fitness, body composition, and insulin sensitivity in overweight children in a school-based exercise program: Arandomized, controlled study. Archives of Pediatrics & Adolescent Medicine. 2005;159:963-968. [pmid: 16203942].
13 Celio AA. Early intervention of eating- and weight-related problems via the internet in overweight adolescents: A randomized controlled trial. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2005;66(4-B):2299.
14 Chanoine JP, Hampl S, Jensen C, Boldrin M, Hauptman J. Effect of orlistat on weight and body composition in obese adolescents: A randomized controlled trial. JAMA. 2005;293:2873-2883. [pmid: 15956632].
15 Collins J, Mattar S, Qureshi F, et al. Initial outcomes of laparoscopic Roux-en-Y gastric bypass in morbidly obese adolescents. Surgery for Obesity & Related Diseases. 2007;3(2):147-52. Apr. [pmid: 17324636].
16 Daniels SR, Long B, Crow S, et al. Cardiovascular effects of sibutramine in the treatment of obese adolescents: Results of a randomized, double-blind, placebo-controlled study. Am J Clin Nutr. 2007;120:e147-e157.
17 Deforche B, De B I, Tanghe A, Debode P, Hills AP, Bouckaert J. Post-treatment phone contact: A weight maintenance strategy in obese youngsters. Int J Obes. 2005;29:543-546.
18 Dolan K, Creighton L, Hopkins G, Fielding G. Laparoscopic gastric banding in morbidly obese adolescents. Obes Surg. 2003;13:101-104. [pmid: 12630622].
19 Dolan K, Fielding G. A comparison of laparoscopic adjustable gastric banding in adolescents and adults. Surg Endosc. 2004;18:45-47. [pmid: 14625730].
20 Doyle CA, Goldschmidt A, Huang C, Winzelberg AJ, Taylor CB, Wilfley DE. Reduction of Overweight and Eating Disorder Symptoms via the Internet in Adolescents: A Randomized Controlled Trial. J.Adolesc Health In press, Corrected proof.
21 Epstein LH, Wing RR, Penner BC, Kress MJ. Effect of diet and controlled exercise on weight loss in obese children. J Pediatr. 1985;107:358-361. [pmid: 4032130].
22 Epstein LH. Effects of family-based behavioral treatment on obese 5-to-8 year-old children. Behavior Therapy. Mar. 1985;Vol 16(2):212.
23 Fielding GA, Duncombe JE. Laparoscopic adjustable gastric banding in severely obese adolescents. Surg Obes Relat Dis. 2005;1:399-405. [pmid: 16925257].
24 Flodmark CE, Ohlsson T, Ryden O, Sveger T. Prevention of progression to severe obesity in a group of obese schoolchildren treated with family therapy. Am J Clin Nutr. 1993;91:880-884.
25 Freemark M, Bursey D. The effects of metformin on body mass index and glucose tolerance in obese adolescents with fasting hyperinsulinemia and a family history of type 2 diabetes. Am J Clin Nutr. 2001;107:E55.
26 Garcia-Morales LM, Berber A, Ias-Lara CC, Lucio-Ortiz C, Del-Rio-Navarro BE, Dorantes-Alvarez LM. Use of sibutramine in obese Mexican adolescents: A 6-month, randomized, double-blind, placebo-controlled, parallel-group trial. Clin Ther. 2006;28:770-782. [pmid: 16861099].
27 Gillis D, Brauner M, Granot E. A community-based behavior modification intervention for childhood obesity. Journal of Pediatric Endocrinology. 2007;197–203, 2007.
28 Godoy-Matos A, Carraro L, Vieira A, et al. Treatment of obese adolescents with sibutramine: a randomized, double-blind, controlled study. Journal of Clinical Endocrinology & Metabolism. 2005;90:1460-1465. [pmid: 15613431].
29 Golan M, Kaufman V, Shahar DR. Childhood obesity treatment: Targeting parents exclusively v. parents and children. Br J Nutr. 2006;95:1008-1015. [pmid: 16611394].
30 Golan M, Weizman A, Apter A, Fainaru M. Parents as the exclusive agents of change in the treatment of childhood obesity. Am J Clin Nutr. 1998;67:1130-1135. [pmid: 9625084].
31 Golley RK, Magarey AM, Baur LA, Steinbeck KS, Daniels LA. Twelve-month effectiveness of a parent-led, family-focused weight-management program for prepubertal children: A randomized, controlled trial. Am J Clin Nutr. 2007;119:517-525.
32 Graf C, Koch B, Bjarnason-Wehrens B, et al. Who benefits from intervention in, as opposed to screening of, overweight and obese children?. Cardiology in the Young. 2006;16(5):474-80. [pmid: 16984699].
33 Graf C, Rost SV, Koch B, et al. Data from the StEP TWO programme showing the effect on blood pressure and different parameters for obesity in overweight and obese primary school children. Cardiol Young. 2005;15:291-298. [pmid: 15865832].
34 Gutin B, Barbeau P, Owens S, et al. Effects of exercise intensity on cardiovascular fitness, total body composition, and visceral adiposity of obese adolescents. American Journal of Clinical Nutrition. 2002;75:818-826. [pmid: 11976154].
35 Inge TH, Garcia VK, Kirk S, et al. Body composition changes after gastric bypass in morbidly obese adolescents. Obes Res. 2004;12:A53.
36 Israel AC, Guile CA, Baker JE, Silverman WK. An evaluation of enhanced self-regulation training in the treatment of childhood obesity. Journal of Pediatric Psychology. 1994;19:737-749. [pmid: 7830214].
37 Israel AC, Stolmaker L, Andrian CA. The effects of training parents in general child management skills on a behavioral weight loss program for children. Behavior Therapy. Mar. 1985;Vol 16(2):180.
38 Johnston CA, Tyler C, Fullerton G, et al. Results of an intensive school-based weight loss program with overweight Mexican American children. Int J Pediatr Obes. 2007;2:144-152. [pmid: 17999280].
39 Johnston CA, Tyler C, McFarlin B, et al. Weight Loss in Overweight Mexican American Children: A Randomized Controlled Trial. Am J Clin Nutr. 2007;120:e1450-e1457.
40 Kalavainen MP, Korppi MO, Nuutinen OM. Clinical efficacy of group-based treatment for childhood obesity compared with routinely given individual counseling. Int J Obes (Lond). 2007;31:1500-1508. [pmid: 17438555].
41 Kang HS, Gutin B, Barbeau P, et al. Physical training improves insulin resistance syndrome markers in obese adolescents. Medicine & Science in Sports & Exercise. 2002;34:1920-1927. [pmid: 12471297].
42 Lawson ML, Kirk S, Mitchell T, et al. One-year outcomes of Roux-en-Y gastric bypass for morbidly obese adolescents: A multicenter study from the Pediatric Bariatric Study Group. J Pediatr Surg. 2006;41:137-143. [pmid: 16410123].
43 Maahs D, de Serna DG, Kolotkin RL, et al. Randomized, double-blind, placebo-controlled trial of orlistat for weight loss in adolescents. Endocrine Practice. 2006;12(1):18-28. Feb. [pmid: 16524859].
44 Mason EE, Scott DH, Doherty C, et al. Vertical banded gastroplasty in the severely obese under age twenty-one. Obes Surg. 1995;5:23-33. [pmid: 10733790].
45 McCallum Z, Wake M, Gerner B, et al. Can Australian general practitioners tackle childhood overweight/obesity? Methods and processes from the LEAP (Live, Eat and Play) randomized controlled trial. Journal of Paediatrics & Child Health. 2005;41(910):488-94. Oct. [pmid: 16150065].
46 McCallum Z, Wake M, Gerner B, et al. Outcome data from the LEAP (Live, Eat and Play) trial: A randomized controlled trial of a primary care intervention for childhood overweight/mild obesity. Int J Obes. 2007;31:630-636.
47 Mellin LM, Slinkard LA, Irwin CE Jr. Adolescent obesity intervention: validation of the SHAPEDOWN program 3987. Journal of the American Dietetic Association. 1987;87:333-338. [pmid: 3819254].
48 Nadler EP, Youn HA, Ginsburg HB, Ren CJ, Fielding GA. Short-term results in 53 US obese pediatric patients treated with laparoscopic adjustable gastric banding. Journal of Pediatric Surgery. discussion 141–2. 2007;42(1):137-41. [pmid: 17208554].
49 Nemet D, Barkan S, Epstein Y, Friedland O, Kowen G, Eliakim A. Short- and long-term beneficial effects of a combined dietary-behavioral-physical activity intervention for the treatment of childhood obesity. Pediatrics. 2005;115(4):e443-9. [pmid: 15687454].
50 Papadia FS, Adami GF, Marinari GM, Camerini G, Scopinaro N. Bariatric surgery in adolescents: A long-term follow-up study. Surg Obes Relat Dis. 2007;3:465-468. [pmid: 17400517].
51 Rand CS, Macgregor AM. Adolescents having obesity surgery: A 6-year follow-up. South Med J. 1994;87:1208-1213. [pmid: 7973919].
52 Reinehr T, de SG, Toschke AM, Andler W. Long-term follow-up of cardiovascular disease risk factors in children after an obesity intervention. American Journal of Clinical Nutrition. 2006;84(3):490-6. [pmid: 16960161].
53 Rooney BL, Gritt LR, Havens SJ, Mathiason MA, Clough EA. Growing healthy families: family use of pedometers to increase physical activity and slow the rate of obesity. WMJ. 2005;104(5):54-60.
54 Saelens BE, Sallis JF, Wilfley DE, Patrick K, Cella JA, Buchta R. Behavioral weight control for overweight adolescents initiated in primary care. Obesity Research. 2002;10:22-32. [pmid: 11786598].
55 Savoye M, Shaw M, Dziura J, et al. Effects of a weight management program on body composition and metabolic parameters in overweight children: a randomized controlled trial. JAMA. 2007;297(24):2697-704. [pmid: 17595270].
56 Senediak C, Spence SH. Rapid versus gradual scheduling of therapeutic contact in a family based behavioural weight control programme for children. Behavioural Psychotherapy. Oct. 1985;Vol 13(4):287.
57 Silberhumer GR, Miller K, Kriwanek S, Widhalm K, Pump A, Prager G. Laparoscopic adjustable gastric banding in adolescents: The Austrian experience. Obes Surg. 2006;16:1062-1067. [pmid: 16901361].
58 Soper RT, Mason EE, Printen KJ, Zellweger H. Gastric bypass for morbid obesity in children and adolescents. J Pediatr Surg. 1975;10:51-58. [pmid: 1117394].
59 Srinivasan S, Ambler GR, Baur LA, et al. Randomized, controlled trial of metformin for obesity and insulin resistance in children and adolescents: Improvement in body composition and fasting insulin. J Clin Endocrinol Metab. 2006;91:2074-2080. [pmid: 16595599].
60 Stanford A, Glascock JM, Eid GM, et al. Laparoscopic Roux-en-Y gastric bypass in morbidly obese adolescents. J Pediatr Surg. 2003;38:430-433. [pmid: 12632362].
61 Strauss RS, Bradley LJ, Brolin RE. Gastric bypass surgery in adolescents with morbid obesity. J Pediatr. 2001;138:499-504. [pmid: 11295712].
62 Sugerman HJ, Sugerman EL, DeMaria EJ, et al. Bariatric surgery for severely obese adolescents. J Gastrointest Surg. 2003;7:102-107. [pmid: 12559191].
63 Tsai WS, Inge TH, Burd RS. Bariatric surgery in adolescents: Recent national trends in use and in-hospital outcome. Archives of Pediatrics & Adolescent Medicine. 2007;161:217-221. [pmid: 17339501].
64 Van Mil EG, Westerterp KR, Kester AD, Delemarre-van de Waal HA, Gerver WJ, Saris WH. The effect of sibutramine on energy expenditure and body composition in obese adolescents. Journal of Clinical Endocrinology & Metabolism. 2007;92(4):1409-14. [pmid: 17264187].
65 Wadden TA, Stunkard AJ, Rich L, Rubin CJ, Sweidel G, McKinney S. Obesity in black adolescent girls: A controlled clinical trial of treatment by diet, behavior modification, and parental support 3928. Am J Clin Nutr. 1990;85:345-352.
66 White MA. Mediators of weight loss in an internet-based intervention for African-American adolescent girls. Dissertation Abstracts International: Section B: The Sciences & Engineering. 2004;Vol 64:Univ.
67 Widhalm K, Dietrich S, Prager G. Adjustable gastric banding surgery in morbidly obese adolescents: Experiences with eight patients. Int J Obes Relat Metab Disord. 2004;28:S42-S45. [pmid: 15543218].
68 Wilfley DE, Stein RI, Saelens BE, et al. Efficacy of maintenance treatment approaches for childhood overweight: A randomized controlled trial. JAMA. 2007;298:1661-1673. [pmid: 17925518].
69 Williamson DA, Martin PD, White MA, et al. Efficacy of an internet-based behavioral weight loss program for overweight adolescent African-American girls. Eating & Weight Disorders: EWD. 2005;10(3):193-203. [pmid: 16277142].
70 Williamson DA, Walden HM, White MA, et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity. 2006;14(7):1231-43. [pmid: 16899804].
71 Woo KS, Chook P, Yu CW, et al. Effects of diet and exercise on obesity-related vascular dysfunction in children. Circulation. 2004;109:1981-1986. [pmid: 15066949].
72 Yitzhak A, Mizrahi S, Avinoach E. Laparoscopic gastric banding in adolescents. Obes Surg. 2006;16:1318-1322. [pmid: 17059740].