# Appendix B. Sample Data Abstraction Forms

Table 1 Sample Data Abstraction Items for Behavioral Intervention Trials

Study Reference | Study characteristics | Patient characteristics | CONSORT Numbers, Retention | Inclusion/Exclusion Criteria
Description of Intervention Groups | Intervention Components | Components Score | Treatment Target Individual vs. Group Treatment | Treatment Intensity
Mean Entry Weight | Intervention phase 2–11 mo | Intervention phase 12–23 mo | Intervention phase 24+ mo | Post-Intervention
BMI Change Mean (SD) | Physiological Outcomes | Other anthropomorphic Outcomes (list) | Other Beneficial Outcomes | Adverse Effects (report findings)
Study Quality | Comment (mention which other outcomes significant), other outcomes reported that are not captured in previous columns

Table 2 Sample abstraction items for supplementary behavioral trials for key questions 2 & 5

Study Reference | Study Characteristics | Patient Characteristics | CONSORT Numbers, Retention | Inclusion/Exclusion Criteria
Description of Intervention Groups | Treatment Target Individual vs. Group Treatment | Treatment Intensity | Mean Entry Weight | Intervention phase 2–11 mo
Intervention phase 12–23 mo | Intervention phase 24+ mo | Post-Intervention | Other anthropomorphic Outcomes | Study Quality
Comment, other outcomes reported that are not captured in previous columns

Table 3 Sample abstraction items for pharmacological intervention trials

Study Reference | Study Characteristics | Patient Characteristics | CONSORT Numbers Retention | Inclusion/Exclusion
Description of Intervention Groups | Dose/Duration | Mean Entry Weight | Intervention phase 6–11 mo | Intervention phase 12–23 mo
Intervention phase 24+ mo | Post-Intervention | Physiological Outcomes Reported | Other anthropomorphic Outcomes | Adverse Effects
Study Quality | Comment (mention which other outcomes significant

Table 4 Sample abstraction items for surgical intervention trials

Study Reference | Country Setting Recruitment Source Years | Surgical Encounter Characteristics | Inclusion/Exclusion | Patient Characteristics (% with DM, IGT, hypertension, hyperlipidemia)
Duration of follow-up | Mean Entry Weight | Change in Weight | Resolution of co-morbidities post surgery | Other positive outcomes
Adverse effects | Study Quality