# Appendix J. Behavior Trials Sorted

Table 1 Behavioral intervention trials, sorted by the presence of organized physical activity

Study Reference | Age Range (Mean) N | Treatment Hours | PA | Fam | Age Grp | Beh Mod
Braet et al 2003^1^ | 10–17 (13) n=76 | 3,520 | 1 | 0 | A | 1
Graf et al 2006 ^2,3^ | 6–11 (8.4) n=276 | 175.5 | 1 | 2 | C | 1
Savoye et al 2007^4^ | 8–16 (12.1) n=174 | 97.5 | 1 | 2 | B | 1
Reinehr et al 2006^5^ | 6–14 (10.4) n=240 | 76 | 1 | 2 | B | 1
Carrel et al 2005^6^ | 12–13 (12.5) n=53 | 67.5 | 1 | 0 | A | 0
Kalavainen 2007^7^ | 6–9 (8.1) n=70 | 45 | 1 | 2 | C | 1
Johnston 2007a^8^ | 10–14 (12.5) n=71 | 41.5 | 1 | 1 | A | 1
Johnston 2007b^9^ | 10–14 (12.4) n=60 | 41.5 | 1 | 1 | A | 1
Nemet et al 2005^10^ | Avg age 11.1 n=54 | 35.75 | 1 | 2 | C | 1
Mellin et al1987^11^ | 12–18 (15.6) n=66 | 24 | 1 | 1 | A | 1
Golley 2007^12^ | 6–9 (8.2) n=111 | 22 | 1 | 2 | C | 1
Flodmark et al, 1993^13^ | 10–11 (Avg NR) n=93 | 24 | 0 | 2 | C | 0
Rooney 2005^14^ | 5–12 (9.7) n=98 | 21 | 0 | 2 | C | 0
Celio/Doyle et al 2007^15^ | 12–18 (14.5) n=43 | 16 | 0 | 0 | A | 1
Senediak et al 1985^16^ | 6–12 (10.3) n=45 | 12 | 0 | 2 | C | 1
Gillis 2007^17^ | 7–16 (10.6) n=27 | 8 | 0 | 1 | B | 0
McCallum et al, 2007^18,19^ | 5–9 (7.4) n=163 | 4 | 0 | 2 | C | 1
Saelens et al 2002^20^ | 12–16 (14.2) n=44 | 3.8 | 0 | 0 | A | 1

Note: Grayed interventions did not show statistically significant weight benefits compared with controls.

PA=Physical Activity (1=included organized PA sessions, 0=no organized PA session)

Fam=Family Involvement (2=parent a primary participant, 1=parent invited to 1–3 treatment sessions, 0=minimal parental involvement)

Age Grp=Age Group (A=adolescent, exclusively aged 10 and older; B=age spans younger children and adolescents; C=exclusively aged 12 and younger)

Beh Mod=Behavior Modification (1=Behavior modification employed, 0=not employed)

Table 2 Behavioral intervention trials, sorted by family involvement, within age group

Study Reference | Age Range (Mean) N | Treatment Hours | PA | Fam | Age Grp | Beh Mod
Johnston 2007a^8^ | 10–14 (12.5) n=71 | 41.5 | 1 | 1 | A | 1
Johnston 2007b^9^ | 10–14 (12.4) n=60 | 41.5 | 1 | 1 | A | 1
Mellin et al1987^11^ | 12–18 (15.6) n=66 | 24 | 1 | 1 | A | 1
Braet et al 2003^1^ | 10–17 (13) n=76 | 3,520 | 1 | 0 | A | 1
Carrel et al 2005^6^ | 12–13 (12.5) n=53 | 67.5 | 1 | 0 | A | 0
Celio/Doyle et al 2007^15^ | 12–18 (14.5) n=43 | 16 | 0 | 0 | A | 1
Saelens et al 2002^20^ | 12–16 (14.2) n=44 | 3.8 | 0 | 0 | A | 1
Savoye et al 2007^4^ | 8–16 (12.1) n=174 | 97.5 | 1 | 2 | B | 1
Reinehr et al 2006^5^ | 6–14 (10.4) n=240 | 76 | 1 | 2 | B | 1
Gillis 2007^17^ | 7–16 (10.6) n=27 | 8 | 0 | 1 | B | 0
Graf et al 2006^2,3^ | 6–11 (8.4) n=276 | 175.5 | 1 | 2 | C | 1
Kalavainen 2007^7^ | 6–9 (8.1) n=70 | 45 | 1 | 2 | C | 1
Nemet et al 2005^10^ | Avg age 11.1 n=54 | 35.75 | 1 | 2 | C | 1
Golley 2007^12^ | 6–9 (8.2) n=111 | 22 | 1 | 2 | C | 1
Flodmark et al, 1993^13^ | 10–11 (Avg NR) n=93 | 24 | 0 | 2 | C | 0
Rooney 2005^14^ | 5–12 (9.7) n=98 | 21 | 0 | 2 | C | 0
Senediak et al 1985^16^ | 6–12 (10.3) n=45 | 12 | 0 | 2 | C | 1
McCallum et al, 2007^18,19^ | 5–9 (7.4) n=163 | 4 | 0 | 2 | C | 1

Note: Grayed interventions did not show statistically significant weight benefits compared with controls.

PA=Physical Activity (1=included organized PA sessions, 0=no organized PA session)

Fam=Family Involvement (2=parent a primary participant, 1=parent invited to 1–3 treatment sessions, 0=minimal parental involvement)

Age Grp=Age Group (A=adolescent, exclusively aged 10 and older; B=age spans younger children and adolescents; C=exclusively aged 12 and younger)

Beh Mod=Behavior Modification (1=Behavior modification employed, 0=not employed)

Table 3 Behavioral intervention trials, sorted by the presence of behavioral management techniques

Study Reference | Age Range (Mean) N | Treatment Hours | PA | Fam | Age Grp | Beh Mod
Braet et al 2003^1^ | 10–17 (13) n=76 | 3,520 | 1 | 0 | A | 1
Graf et al 2006^2,3^ | 6–11 (8.4) n=276 | 175.5 | 1 | 2 | C | 1
Savoye et al 2007^4^ | 8–16 (12.1) n=174 | 97.5 | 1 | 2 | B | 1
Reinehr et al 2006^5^ | 6–14 (10.4) n=240 | 76 | 1 | 2 | B | 1
Kalavainen 2007^7^ | 6–9 (8.1) n=70 | 45 | 1 | 2 | C | 1
Johnston 2007a^8^ | 10–14 (12.5) n=71 | 41.5 | 1 | 1 | A | 1
Johnston 2007b^9^ | 10–14 (12.4) n=60 | 41.5 | 1 | 1 | A | 1
Nemet et al 2005^10^ | Avg age 11.1 n=54 | 35.75 | 1 | 2 | C | 1
Mellin et al1987^11^ | 12–18 (15.6) n=66 | 24 | 1 | 1 | A | 1
Golley 2007^12^ | 6–9 (8.2) n=111 | 22 | 1 | 2 | C | 1
Celio/Doyle et al 2007^15^ | 12–18 (14.5) n=43 | 16 | 0 | 0 | A | 1
Senediak et al 1985^16^ | 6–12 (10.3) n=45 | 12 | 0 | 2 | C | 1
McCallum et al, 2007^18,19^ | 5–9 (7.4) n=163 | 4 | 0 | 2 | C | 1
Saelens et al 2002^20^ | 12–16 (14.2) n=44 | 3.8 | 0 | 0 | A | 1
Carrel et al 2005^6^ | 12–13 (12.5) n=53 | 67.5 | 1 | 0 | A | 0
Flodmark et al, 1993^13^ | 10–11 (Avg NR) n=93 | 24 | 0 | 2 | C | 0
Rooney 2005^14^ | 5–12 (9.7) n=98 | 21 | 0 | 2 | C | 0
Gillis 2007^21^ | 7–16 (10.6) n=27 | 8 | 0 | 1 | B | 0

Note: Grayed interventions did not show statistically significant weight benefits compared with controls.

PA=Physical Activity (1=included organized PA sessions, 0=no organized PA session)

Fam=Family Involvement (2=parent a primary participant, 1=parent invited to 1–3 treatment sessions, 0=minimal parental involvement)

Age Grp=Age Group (A=adolescent, exclusively aged 10 and older; B=age spans younger children and adolescents; C=exclusively aged 12 and younger)

Beh Mod=Behavior Modification (1=Behavior modification employed, 0=not employed)

## References

1 Braet C, Tanghe A, Bode PD, Franckx H, Winckel MV. Inpatient treatment of obese children: A multicomponent programme without stringent calorie restriction. Eur J Pediatr. 2003;162:391-396. [pmid: 12756560].
2 Graf C, Rost SV, Koch B, et al. Data from the StEP TWO programme showing the effect on blood pressure and different parameters for obesity in overweight and obese primary school children. Cardiol Young. 2005;15:291-298. [pmid: 15865832].
3 Graf C, Koch B, Bjarnason-Wehrens B, et al. Who benefits from intervention in, as opposed to screening of, overweight and obese children?. Cardiology in the Young. 2006;16(5):474-80. [pmid: 16984699].
4 Savoye M, Shaw M, Dziura J, et al. Effects of a weight management program on body composition and metabolic parameters in overweight children: a randomized controlled trial. JAMA. 2007;297(24):2697-704. [pmid: 17595270].
5 Reinehr T, de SG, Toschke AM, Andler W. Long-term follow-up of cardiovascular disease risk factors in children after an obesity intervention. American Journal of Clinical Nutrition. 2006;84(3):490-6. [pmid: 16960161].
6 Carrel AL, Clark RR, Peterson SE, Nemeth BA, Sullivan J, Allen DB. Improvement of fitness, body composition, and insulin sensitivity in overweight children in a school-based exercise program: Arandomized, controlled study. Archives of Pediatrics & Adolescent Medicine. 2005;159:963-968. [pmid: 16203942].
7 Kalavainen MP, Korppi MO, Nuutinen OM. Clinical efficacy of group-based treatment for childhood obesity compared with routinely given individual counseling. Int J Obes (Lond). 2007;31:1500-1508. [pmid: 17438555].
8 Johnston CA, Tyler C, Fullerton G, et al. Results of an intensive school-based weight loss program with overweight Mexican American children. Int J Pediatr Obes. 2007;2:144-152. [pmid: 17999280].
9 Johnston CA, Tyler C, McFarlin B, et al. Weight Loss in Overweight Mexican American Children: A Randomized Controlled Trial. Am J Clin Nutr. 2007;120:e1450-e1457.
10 Nemet D, Barkan S, Epstein Y, Friedland O, Kowen G, Eliakim A. Short- and long-term beneficial effects of a combined dietary-behavioral-physical activity intervention for the treatment of childhood obesity. Pediatrics. 2005;115(4):e443-9. [pmid: 15687454].
11 Mellin LM, Slinkard LA, Irwin CE Jr. Adolescent obesity intervention: validation of the SHAPEDOWN program 3987. Journal of the American Dietetic Association. 1987;87:333-338. [pmid: 3819254].
12 Golley RK, Magarey AM, Baur LA, Steinbeck KS, Daniels LA. Twelve-month effectiveness of a parent-led, family-focused weight-management program for prepubertal children: A randomized, controlled trial. Am J Clin Nutr. 2007;119:517-525.
13 Flodmark CE, Ohlsson T, Ryden O, Sveger T. Prevention of progression to severe obesity in a group of obese schoolchildren treated with family therapy. Am J Clin Nutr. 1993;91:880-884.
14 Rooney BL, Gritt LR, Havens SJ, Mathiason MA, Clough EA. Growing healthy families: family use of pedometers to increase physical activity and slow the rate of obesity. WMJ. 2005;104(5):54-60. [pmid: 16138517].
15 Celio AA. Early intervention of eating- and weight-related problems via the internet in overweight adolescents: A randomized controlled trial. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2005;66(4-B):2299.
16 Senediak C, Spence SH. Rapid versus gradual scheduling of therapeutic contact in a family based behavioural weight control programme for children. Behavioural Psychotherapy. Oct. 1985;Vol 13(4):287.
17 Gillis D, Brauner M, Granot E. A community-based behavior modification intervention for childhood obesity. Journal of Pediatric Endocrinology. 2007;197–203, 2007.
18 McCallum Z, Wake M, Gerner B, et al. Can Australian general practitioners tackle childhood overweight/obesity? Methods and processes from the LEAP (Live, Eat and Play) randomized controlled trial. Journal of Paediatrics & Child Health. 2005;41(910):488-94. Oct. [pmid: 16150065].
19 McCallum Z, Wake M, Gerner B, et al. Outcome data from the LEAP (Live, Eat and Play) trial: A randomized controlled trial of a primary care intervention for childhood overweight/mild obesity. Int J Obes. 2007;31:630-636.
20 Saelens BE, Sallis JF, Wilfley DE, Patrick K, Cella JA, Buchta R. Behavioral weight control for overweight adolescents initiated in primary care. Obesity Research. 2002;10:22-32. [pmid: 11786598].
21 Bryant MJ, Lucove JC, Evenson KR, Marshall S. Measurement of television viewing in children and adolescents: a systematic review. Obesity Reviews. 2007;8(3):197-209. [pmid: 17444962].