# Appendix A: Exact Search String

Database: MEDLINE, Database of Abstracts of Reviews of Effectiveness, Education Resource Information Center, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, NICE, PsycInfo

<2003 to December 2007>

Search Strategy:

--------------------------------------------------------------------------------

1 exp “Obesity”/
2 “Weight-Gain”/
3 “Weight-Loss”/
4 (obesity or obese).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
5 (weight gain or weight loss).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
6 (overweight or over weight or overeat$ or over eat$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
7 weight change$.mp.
8 ((bmi or body mass index) adj2 (gain or loss or change)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
9 weight maintenance.mp.
10 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11 limit 10 to child <6 to 12 years>
12 limit 10 to adolescent <13 to 18 years>
13 limit 10 to preschool child <2 to 5 years>
14 (child$ or adolescen$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
15 (teenage$ or young people or young person or young adult$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
16 (schoolchildren or school children).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
17 (pediatr$ or paediatr$).ti,ab.
18 (boys or girls or youth or youths).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
19 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18
20 exp “Behavior-Therapy”/
21 Social Support/
22 Family-Therapy/
23 exp “Psychotherapy-Group”/
24 ((psychological or behavio?r$) adj (therapy or modif$ or strateg$ or intervention$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
25 (group therapy or family therapy or cognitive therapy).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
26 ((lifestyle or life style) adj (chang$ or intervention$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
27 counsel?ing.mp.
28 social support.mp.
29 (peer adj2 support).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
30 ((children adj3 parent$) and therapy).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
31 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30
32 exp OBESITY/dt [Drug Therapy]
33 exp Anti-Obesity Agents/
34 lipase inhibitor$.mp.
35 (orlistat or xenical or tetrahydrolipstatin).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
36 (appetite adj (suppressant$ or depressant$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
37 sibutramine.mp. or meridia.ti,ab. [mp=title, original title, abstract, name of substance word, subject heading word]
38 (dexfenfluramine or fenfluramine or phentermine).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
39 bulking agent$.mp.
40 (methylcellulose or celevac).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
41 ((antiobesity or anti obesity) adj (drug$ or agent$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
42 guar gum.mp.
43 (metformin or glucophage).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
44 (fluoxetine or prozac).mp.
45 (Sertraline or zoloft).mp.
46 Diethylpropion.mp.
47 zonisamide.mp.
48 topiramate.mp.
49 (Octreotide or somatostatin or sandostatin).mp.
50 (Amantadine or symmetrel).mp.
51 (Glucagon-Like Peptide 1 or glp-1).mp.
52 (rimonabant or acomplia).mp.
53 (SLV 319 or SLV319).mp.
54 exenatide.mp.
55 liraglutide.mp.
56 vildagliptin.mp.
57 sitagliptin.mp.
58 (qnexa or contrave or excalia).mp.
59 exp OBESITY/dh [Diet Therapy]
60 “Diet-Fat-Restricted”/
61 “Diet-Reducing”/
62 “Diet-Therapy”/
63 “Fasting”/
64 (diet or diets or dieting).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
65 (diet$ adj (modif$ or therapy or intervention$ or strateg$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
66 (low calorie or calorie control$ or healthy eating).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
67 (fasting or modified fast$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
68 exp “Dietary-Fats”/
69 (fruit or vegetable$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
70 (high fat$ or low fat$ or fatty food$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
71 formula diet$.mp.
72 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71
73 “Exercise”/
74 “Exercise-Therapy”/
75 exercis$.mp.
76 (aerobics or physical therapy or physical activity or physical inactivity).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
77 (fitness adj (class$ or regime$ or program$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
78 (physical training or physical education).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
79 dance therapy.mp.
80 sedentary behavio?r reduction.mp.
81 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80
82 exp OBESITY/su [Surgery]
83 “Surgical-Staplers”/
84 “Surgical-Stapling”/
85 “Lipectomy”/
86 “Gastric-Bypass”/
87 “Gastroplasty”/
88 (dental splinting or jaw wiring).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
89 (gastroplasty or gastric band$ or gastric bypass).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
90 (intragastric balloon$ or vertical band$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
91 (stomach adj (stapl$ or band$ or bypass)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
92 biliopancreatic diversion$.mp.
93 liposuction.mp.
94 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93
95 exp “Alternative-Medicine”/
96 (alternative medicine or complementary therap$ or complementary medicine).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
97 (hypnotism or hypnosis or hypnotherapy).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
98 (acupuncture or homeopathy).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
99 (chinese medicine or indian medicine or herbal medicine or ayurvedic).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
100 95 or 96 or 97 or 98 or 99
101 ((diet or dieting or slim$) adj (club$ or organi?ation$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
102 (weightwatcheR$ or weight watcher$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
103 (correspondence adj (course$ or program$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
104 (fat camp$ or diet$ camp$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
105 101 or 102 or 103 or 104
106 (family intervention$ or parent$ intervention$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
107 (parent$ adj2 (behavio?r or involve$ or control$ or attitude$ or educat$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
108 106 or 107
109 (systematic$ review$ or systematic$ overview$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
110 (quantitative$ review$ or quantitative$ overview$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
111 Evidence-Based Medicine/
112 evidence based review$.mp.
113 exp “Controlled-Clinical-Trials”/
114 exp “Research-Design”/
115 ((singl$ or doubl$ or trebl$ or tripl$) adj5 (blind$ or mask$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
116 (CONTROLLED-CLINICAL-TRIAL or RANDOMIZED CONTROLLED TRIAL or META-ANALYSIS).pt.
117 (control$ and (trial$ or stud$ or evaluation$ or experiment$)).ti,ab.
118 (comparison group$ or control group$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
119 random$.ti,ab.
120 matched pairs.mp.
121 (outcome study or outcome studies).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
122 (quasiexperimental or quasi experimental or pseudo experimental).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
123 (nonrandomi?ed or non randomi?ed or pseudo randomi?ed).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
124 cohort studies/
125 (cohort adj (study or studies)).ti,ab.
126 cohort analys$.ti,ab.
127 case series.ti,ab.
128 longitudinal studies/
129 longitudinal$.ti,ab.
130 follow-up studies/
131 (follow up adj (study or studies)).ti,ab.
132 prospective studies/
133 prospective$.ti,ab.
134 109 or 110 or 111 or 112 or 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128 or 129 or 130 or 131 or 132 or 133
135 10 and 19
136 32 or 33 or 34 or 36 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58
137 134 and 135 and 136
138 limit 137 to yr=“2003 - 2007”
139 31 or 35 or 37 or 72 or 81 or 94 or 100 or 105 or 108
140 134 and 135 and 139
141 limit 140 to yr=“2005 - 2007”
142 138 or 141
143 limit 142 to animals
144 limit 142 to humans
145 143 not 144
146 142 not 145
147 limit 146 to english language