# Appendixes

Appendix A: Exact Search String

Appendix B. Sample Data Abstraction Forms

Appendix C. Evidence Tables

Appendix D. List of excluded studies

Appendix E. Technical Expert Panel/Peer Reviewers

Appendix F. Pending Assessment

Appendix G. Study eligibility criteria

Appendix H. Quality rating criteria

Appendix I. Search results and article flow

Appendix J. Behavior Trials Sorted

Appendix K. Glossary