# Selected Clinical Abbreviations Used in the Evidence Tables

bid: twice daily

BP: benzoyl peroxide

cyp: cyproterone

E: erithromycin

EE: ethinyl estradiol

GI: gastrointestinal

gyn: gynecological

NS: not significant

OTC: over the counter

qd: once a day

qhs: once at bedtime

qid: four times a day

qod: every other day

rbg: retinyl beta-glucuronide

sqrt: square root

sul: sulfur

tfd: fractionated dialyzable transfer factor

tid: three times a day

tet: tetracycline

tret: tretinoin

VAS: Visual Analogue Scale

wks: week

y/yr: year