# Evidence Tables

SUMMARY TABLE. Trials included in the article review

Trial information | Treatments Time points (wks) | Participants | | Outcomes | Methodological Qualifications | Authors' Bottom Line
#1 Adams, 1991 Wellington, New Zealand Parallel | Doxycycline Fusidin cream 2, 4, 6, 10 | n=110 female 31 male 79 Age 18.0 y | Mild/mod | Overall change/investigator Overall change/patient Side effects Total lesions (count) | ↑ Randomized. Specific population. ↓ Patient not blinded. | Topical fusidin was as effective as oral doxycycline.
#2 Adams, 1970 Palo Alto, USA Parallel split face | Vehicle Delta-0.2%-chlormadione Delta-5%-chlormadione 7 | n=20 female 9 male 11 | Can't say | Overall change/patient Overall change/physician | ↑ No losses to followup. ↓ Not randomized. | Neither 0.2% delta chlormadinone acetate nor 5% delta chlormadinone acetate cream had any treatment effect on acne.
#3 Agrawal, 1985 Varanasi, India Parallel | Placebo Zinc sulfate 12 | n=42 female 11 male 31 | Can't say | Overall change/physician Severity (Agrawal) | ↓ Arms not comparable. | Oral zinc sulphate was no more effective than placebo in mild acne but improvement was seen in patients with pustules, nodules and cysts.
#4 Akamatsu, 1996 Osaka, Japan Parallel | Roxithromycin (300) Roxithromycin (150) 8 | n=30 female 28 male 2 Age 14.0-26 y | Can't say | Severity change (Akamatsu) | ↑ No losses to followup. General population. ↓ Not randomized. Patient not blinded. Enroller not blinded. Outcome assessor not blinded. Arms not comparable. Execution not as designed. | A daily dose of 300 mg of roxithromycin was more effective than a lower dose of 150mg in treating severe acne.
#5 Al Mishari, 1986 Kuwait Parallel | Isotretinoin (0.5) Isotretinoin (0.3) Isotretinoin (0.1) 16 | n=30 female 16 male 14 Age 23.1 y | Sev | Overall change/physician Side effects | ↑ No losses to followup. Referral population. ↓ Not randomized. Patient not blinded. Enroller not blinded. Outcome assessor not blinded. | Best clinical response with lowest range of side effects was achieved with a dosage of 0.3 mg/kg.
#6 Al Mishari, 1987 Kuwait Parallel | Erythromycin Tetracycline 16 | n=40 female 22 male 18 Age 12.5-26 y | Can't say | Severity change Side effects | ↑ No losses to followup. ↓ Not randomized. Patient not blinded. Enroller not blinded. Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. | Tetracycline and erythromycin, at low doses, were safe and effective in treating acne vulgaris.
#10 Anderson, 1976 Cincinnati, USA Parallel | Vehicle (topical) + placebo (oral) Tetracycline (topical) + placebo (oral) Tetracycline (oral) + vehicle (topical) 1, 2, 3, 4, 5, 6, 7, 8 | n=60 female 0 male 60 | Mod | Severity (Anderson) Severity change | ↓ Arms not comparable. Execution not as designed. | Oral and topical tetracycline were each as better than placebo in reducing acne severity.
#12 Anonymous. 1963 Scotland Parallel multicenter | Placebo Vitamin A 12 | n=80 female 34 male 46 | Can't say | Overall change/dermatologist Overall change/generalist | ↑ Data shows outcome assessor blinded. Local population. ↓ Arms not comparable. | No evidence that Vitamin A improved acne.
#13 Anonymous. 1974 UK Parallel split face multicenter | Tretinoin Methyl prednisolone + neomycin 2, 4, 8 | n=68 female 76 male 60 | Mild/mod/sev | Change (GPRG) Comedone-free Comedones (count) Inter-treatment preference/patient Side effects | ↓ Major losses to followup. Inconsistent ascertainment across arms. | No significant difference was found between tretinoin lotion and methylprednisolone lotion.
#15 Ashorn, 1985 Tampere, Finland Parallel | Saline Fractionated tfd Unfractionated tfd 12 | n=39 female 21 male 18 Age 21.5 y | Sev | Overall change | ↑ No losses to followup. ↓ Arms not comparable. | Human dialyzable transfer factor produced the same clinical improvement in acne as placebo.
#16 Ashurst, 1964 Manchester, UK Cross-over matched | Hydroxyquinoline + benzoyl peroxide Hydroxyquinoline + benzoyl peroxide + hydrocortisone 8 | n=54 | Mild/mod | Cysts change [cystic] Papules change [papules] Pustules change [pustular] Severity change | ↑ Data show patient blinded. Data shows enroller blinded. Data shows outcome assessor blinded. Referral population. | Quinoderm-hydrocortisone was superior to quinoderm alone.
#17 Balambal, 1985 Madras, India Parallel | Ocimum basilicum Tetracycline 8 | n=51 female 18 male 33 Age 11.0-30 y | Can't say | Severity change (grade) | ↓ Patient not blinded. Enroller not blinded. Major losses to followup. | Responses to tetracycline and osmium basilicum leaves were similar; Leaves were much less expensive.
#18 Bassett, 1990 Sydney, Australia Parallel | Benzoyl peroxide Tea tree oil 4, 8, 12 | n=124 female 60 male 64 Age 19.7 y | Mod | Inflammatory (count) Non-inflammatory (count) Unwanted effects | ↑ Data shows enroller blinded. No losses to followup. Data shows outcome assessor blinded. | Tea tree oil may be a useful alternative treatment for mild to moderate acne.
#19 Becker, 1965 Duluth, USA Parallel multicenter | Placebo 16-epiestriol-3-allyl ether 12 | n=134 female 87 male 47 | Can't say | Oiliness Severity change | ↓ Not randomized. Major losses to followup. Arms not comparable. | No significant difference in acne or in reduction of oiliness with respect to placebo.
#20 Becker, 1981 San Diego, USA Parallel multicenter | Vehicle Clindamycin hydrochloride Clindamycin phosphate 2, 4, 6, 8 | n=358 female 224 male 133 Age 21.5 y | Mod | Diarrhea Overall change/patient Papules (count) Papules change (count) Pustules (count) Pustules change (count) | | Topical clindamycin hydrochloride and topical clindamycin phosphate were both effective and similar to one another.
#21 Bettley, 1976 Middlesex, UK Cross-over | Phisohex Triclosan 6, 12 | n=34 | Mild/mod/sev | Overall change/patient Overall change/physician Side effects | ↓ Enroller not blinded. Outcome assessor not blinded. | The mixture of triclosan and a detergent was as effective as Phisohex^®^.
#22 Bladon, 1986 Leeds, UK Parallel | Tetracycline + placebo Azelaic acid + placebo 4, 8, 16, 24 | n=45 female 0 male 45 Age 18.5 y | Mod/sev | Abdominal pain Face severity (Leeds) Inflammatory (count) Non-inflammatory (count) Non-inflammatory (count/median) Total inflammatory (count) Total lesions (count) Total lesions (count/median) Total severity (Leeds) | ↓ Not randomized. Major losses to followup. | Topical azelaic acid was as effective as systemic tetracycline.
#23 Blaney, 1976 Cincinnati, USA Parallel | Placebo (topical) + tetracycline hydrochloride (oral) Placebo (topical) + placebo (oral) Tetracycline hydrochloride (topical) + placebo (oral) 2, 4, 6, 8, 10, 13 | n=75 female 12 male 63 Age 16.3±2.3 y | Mod | Severity change (Cook) Severity change (Cook) | ↑ Randomized. Data shows outcome assessor blinded. | Tetracycline reduced acne severity more than placebo.
#24 Bleeker, 1983 lidkoping, Sweden Parallel | Erythromycin (stearate) Erythromycin (base) 2 | n=40 Age 20.2 y | Mod | Papules (count) Side effects | ↑ Randomized. | Oral erythromycin was effective in the treatment of acne vulgaris.
#25 Bleeker, 1981 Lidkoping, Sweden Parallel multicountry | Erythromycin stearate + placebo Doxycycline + placebo 2, 6 | n=56 female 29 male 27 Age 20.3 y | Mod | Inflammatory change (%) Severity (Kligman) | ↑ Randomized. Data show patient blinded. Data shows enroller blinded. No losses to followup. Data shows outcome assessor blinded. ↓ Arms not comparable. | Both erythromycin and doxycycline produced improvement after 2 weeks and neither had side effects.
#28 Bojar, 1994 Leeds, UK Parallel | Erythromycin + zinc acetate Erythromycin 4, 8, 12 | n=45 female 15 male 30 Age 14.1 y | Mild/mod | Inflammatory (count) Non-inflammatory (count) Severity (Leeds) | ↑ Randomized. ↓ Arms not comparable.
#29 Borglund, 1984 Stockholm, Sweden Parallel | Tetracycline + vehicle Clindamycin phosphate + placebo 4, 8 | n=20 female 13 male 7 Age 18.0 y | Mod | Nodules (count) Papules (count) Pustules (count) | ↑ No losses to followup. ↓ Arms not comparable. | No clinical difference was found between topical clindamycin and oral tetracycline.
#30 Borglund, 1991 Stockholm, Sweden Parallel multicountry | Meclocycline + benzoyl peroxide Meclocycline Benzoyl peroxide 6, 10 | n=102 female 54 male 48 Age 19.0 y | Mod | Adverse effects Comedones (count) Papules (count) Pustules (count) Skin discoloration | ↑ No losses to followup. ↓ Outcome assessor not blinded. Arms not comparable. | For acne patients susceptible to skin irritation from benzoyl peroxide, combined treatment with benzoyl peroxide and a topical antibiotic was advantageous.
#31 Bottomley, 1993 Leeds, UK Parallel split face | Fulguration Tretinoin 2, 4 | n=11 female 10 male 1 Age 22.0-36 y | Mild | Closed comedone change (%) Overall change/patient | Data shows outcome assessor blinded. Referral population. ↓ Patient not blinded. | Fulguration can offer a simple but effective treatment for eliminating white heads.
#32 Bottomley, 1993 Leeds, UK Parallel split face | Electrocautery Fulguration 4 | n=12 female 8 male 4 Age 23.0 y | Mild | Large comedone change (%) Small comedones change (%) | Data shows outcome assessor blinded. Referral population. ↓ Patient not blinded. | Use electrocautery on large closed comedones.
#33 Braathen, 1984 Oslo, Norway Parallel | Vehicle (oral) + vehicle (topical) Tetracycline + vehicle Clindamycin + vehicle 8 | n=87 female 44 male 43 Age 20.3 y | Mild | Diarrhea Inflammatory (count) Overall change/patient Overall change/physician | | Both oral tetracycline and topical clindamycin reduced the number of acne lesions.
#34 Bradford, 1974 Birmingham, USA Parallel | Vitamin A Vehicle 12 | n=75 Age 13.0-30 y | Mild/mod | Response Side effects | ↑ No losses to followup. Referral population. ↓ Not randomized. Enroller not blinded. Outcome assessor not blinded. Arms not comparable. | Topical vitamin A was more effective than placebo.
#35 Bradford, 1974 Birmingham, USA Parallel matched | Vehicle Vitamin A 12 | n=72 female 23 male 49 Age 15.6±2.7 y | Mild/mod | Comedones (group count) Comedones [female] (count) Comedones [male] (count) Overall change Overall change [female] Overall change [male] Papules (group count) Papules [female] (group count) Papules [male] (group count) Pustules (total count) Pustules [female] (total count) Pustules [male] (total count) | ↑ Randomized. No losses to followup. ↓ Outcome assessor not blinded. Arms not comparable. | Topical vitamin A was more effective than placebo.
#36 Brandt, 1994 Helsinki, Finland Parallel multicenter | Tetracycline Erythromycin acistrate 12, 24 | n=60 female 19 male 41 Age 21.0±4.4 y | Mod/sev | Back severity (Harcup/median) Chest severity (Harcup/median) Face/neck severity (Harcup/median) Side effects | ↑ Local population. | Erythromycin acistrate was a safe, well tolerated alternative to tetracycline for systemic treatment of acne.
#37 Brookes, 1978 Lancaster, UK Parallel multicenter | Chloramphenicol + hydrocortisone Tretinoin 2, 4, 6, 8, 10, 12 | n=56 Age 18.0-22 y | Mod | Comedones change (count) Cysts change (count) Overall change/patient Overall change/patient (vas) Papules change (count) Pustules change (count) | ↑ Randomized. ↓ Patient not blinded. Major losses to followup. Outcome assessor not blinded. | Chloramphenicol/hydrocort isone and tretinoin showed similar activity over 12 weeks.
#38 Bucknall, 1977 St. Georges, UK Parallel | Benzoyl peroxide Tretinoin 12 | n=97 female 39 male 58 Age 12.0-36 y | Mod | Comedones (count) Overall change/patient Overall change/physician Papules (count) Pustules (count) Side effects | ↓ Patient not blinded. Inconsistent ascertainment across ascertainment across arms. Arms not comparable. | Tretinion produced greater improvement than benzoyl peroxide.
#39 Burke, 1983 Leeds, UK Parallel matched | Placebo Erythromycin (topical) Benzoyl peroxide 4, 8 | n=94 female 19 male 70 Age 18.8±18.9 y | Mild/mod/sev | Inflammatory (count) Inflammatory (counts) Non-inflammatory (count) Severity (Leeds) Total Lesions (count) Withdrawal due to side effects | ↓ Not randomized. Inconsistent ascertainment across arms. | Benzoyl peroxide and topical erythromycin are equally effective in reducing the number of superficial inflamed lesions.
#40 Burton, 1990 Bristol, UK Parallel multicenter | Tetracycline (topical) + tetracycline (oral) Placebo + tetracycline (oral) 4, 8, 12, 16 | n=85 female 44 male 38 Age 20.4±4.9 y | Can't say | Adverse reactions Adverse-gastrointestinal Adverse-skin Overall change/patient, investigator Severity (Cook) | ↑ No losses to followup. ↓ Not randomized. | Topical tetracycline, in combination with 8 weeks of oral tetracycline was well accepted by patients and reduced acne severity at 16 weeks.
#41 Cahn, 1959 Phildelphia, USA Cross-over | Placebo Sulfadimethoxine 5, 10 | n=134 female 107 male 27 Age 15.0-41 y | Sev | Inter-treatment preference/physician | ↑ No losses to followup. | Sulfadlimethoxine was a “useful and safe” agent in the treatment of acne vulgaris.
#42 Cambazard, 1998 France Parallel multicenter | Tretinoin Tretinoin + clindamycin 2, 4, 8, 12 | n=40 Age 14.0-26 y | Mod/sev | Inflammatory change (%) Non-inflammatory change (%) Severity (Cook) | No losses to followup. ↓ Inconsistent ascertainment across arms. Arms not comparable. | Combination more effective in inflamed acne.
#43 Cambazard, 1998 France Parallel multicenter | Tretinoin Tretinoin + clindamycin 2, 4, 8, 12 | n=161 Age 14.0-26 y | Mod/sev | Inflammatory change (%) Non-inflammatory change (%) Severity (Cook) | No losses to followup. ↓ Inconsistent ascertainment across arms. Arms not comparable. | Combination more effective than tretinoin alone.
#44 Cambazard, 1998 France Parallel multicenter | Tretinoin Tretinoin + clindamycin 2, 4, 8, 12 | n=157 Age 14.0-26 y | Mod/sev | Inflammatory change (%) Non-inflammatory change (%) Severity (Cook) | No losses to followup. ↓ Inconsistent ascertainment across arms. Arms not comparable. | Combination not demonstrated superior to tretinoin in Velac gel^®^.
#45 Cambazard, 1998 France Parallel multicenter | Clindamycin Tretinoin + clindamycin 2, 4, 8, 12 | n=209 Age 14.0-26 y | Mod/sev | Inflammatory change (%) Non-inflammatory change (%) Severity (Cook) | No losses to followup. ↓ Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. | Combination superior for inflammatory acne.
#46 Cambazard, 1998 France Parallel multicenter | Clindamycin Tretinoin + clindamycin 2, 4, 8, 12 | n=40 Age 14.0-26 y | Mod/sev | Inflammatory change (%) Non-inflammatory change (%) Severity (Cook) | No losses to followup. ↓ Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. | Combination not superior to clindamycin.
#47 Cambazard, 1998 France Parallel multicenter | Clindamycin Tretinoin + clindamycin 2, 4, 8, 12 | n=162 Age 14.0-26 y | Mod/sev | Inflammatory change (%) Non-inflammatory change (%) Severity (Cook) | No losses to followup. ↓ Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. | Combination superior to clindamycin for non-inflammatory acne.
#48 Carlborg, 1986 Halmstad, Sweden Parallel multicenter | Levonorgestrel + ethinyl estradiol (0.030) Cyproterone + ethinyl estradiol (0.035) Cyproterone + ethinyl estradiol (0.05) 16, 24 | n=133 female 133 male 0 Age 15.0- y | Can't say | Discontinuation due to side effects Total lesions change Total lesions change (%) | ↑ Data shows enroller blinded. | Lower frequency of side effects in the 35 mcg group.
#49 Caron, 1997 Sophia Antipoli, France Parallel split face | Tretinoin Adapalene 2 | n=15 female 26 male 4 Age 28.4±6.3 y | Mild/mod | Burning severity (patient) Desquamation severity (investigator) Edema severity (investigator) Erythema severity (investigator) Papules severity Pruritis severity (patient) Tightness severity (patient) Vesicle severity (investigator) | ↑ No losses to followup. Data shows outcome assessor blinded. ↓ Not randomized. Patient not blinded. | Adapalene was better tolerated than tretinoin.
#52 Cavicchini, 1989 Milan, Italy Parallel multicenter | Benzoyl peroxide Azelaic acid 2, 4, 6, 12, 16, 20, 24 | n=309 | Mild | Good/excellent response (%) Inflammatory (count) Inflammatory (count/median) Local side effects Overall change/physician (%) | ↓ Enroller not blinded. Major losses to followup. Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. Execution not as designed. | Treatments showed equal benefit. Benzoyl peroxide produced a more rapid effect on cutaneous lesions; azelaic acid applications were better tolerated.
#53 Chalker, 1983 NY, USA Parallel | Erythromycin + benzoyl peroxide Benzoyl peroxide Vehicle Erythromycin 2, 4, 6, 8, 10 | n=177 female 81 male 115 Age 15.0-30 y | Mod/sev | Comedones change (%) Inflammatory change (%) Papules change (%) Pustules change (%) | ↓ Inconsistent ascertainment across arms. | The combination is more effective than vehicle.
#54 Chalker, 1987 Augusta, USA Parallel multicenter | Vehicle Isotretinoin 2, 5, 8, 11, 14 | n=313 female 112 male 156 Age 19.5 y | Can't say | Erythema score Inflammatory change (%) Non-inflammatory change (%) Peeling score Severity change (Cook %) | ↑ Specific population. ↓ Inconsistent ascertainment across arms. | Isotretinoin 0.05% gel is useful for mild to moderately severe acne.
#55 Charoenvisal, 1996 Songkhla, Thailand Parallel | Desogestrel + ethinyl estradiol Cyproterone + ethinyl estradiol (.05) 4, 12, 24 | n=66 female 66 male 0 Age 16.0-30 y | Can't say | Overall change/patient [center a] Overall change/patient [center b] Severity [center a] (Charoenvisal) Severity [center b] (Charoenvisal) Side effects | ↓ Patient not blinded. Enroller not blinded. Inconsistent ascertainment across arms. Outcome assessor not blinded. | Decreased mean acne score occured with both ethinyl estradiol-desogestrel and ethinyl estradiol-cyproterone. No difference between groups was reported.
#56 Christian, 1975 Salt Lake City, USA Parallel | Vehicle Clindamycin 1, 2, 4, 6, 10, 13 | n=98 female 32 male 49 Age 21.0 y | Mod/sev | Comedones change (%) Pustules change (%) Side effects | | Clindamycin is effective in treating moderate-severe acne.
#57 Christiansen, 1979 Copenhagen, Denmark Parallel multicenter | Vitamin A + placebo Vehicle + oxytetracycline Vitamin A + oxytetracycline 2, 4, 8 | n=238 female 135 male 103 Age 11.0-44 y | Can't say | Comedones change Papules change Pustules change Side effects | ↑ Data shows enroller blinded. ↓ Major losses to followup. | Vitamin A was better than oxytetracycline for comedones and, less effective for pustules, and equally good for papules. Vitamin A produced more local side effects.
#58 Christiansen, 1977 Copenhagen, Denmark Parallel multicenter | Vehicle Tretinoin (0.05%) Tretinoin (0.02%) 4, 8 | n=256 | Sev | Comedones (Christiansen) Comedones severity (Christiansen) Nodes+cysts (score) Papules severity (Christiansen) Pustules (score) Side effects | ↓ Major losses to followup. | 0.05% tretinoin was more effective than 0.02% tretinoin and placebo for papules and comedones but not pustules. Side effects of 0.05% and 0.02% were similar.
#59 Christiansen, 1976 Arhus, Denmark Parallel | Motretinide Tretinoin 2, 4, 6, 8 | n=37 female 20 male 11 Age 21.0 y | Mild | Burning Erythema desquamation Total lesions Total lesions change (count/median) | ↑ Referral population. ↓ Major losses to followup. | Motretinide and tretinoin 0.05% were equivalent but authors acknowledge study was too small to detect differences.
#60 Christiansen, 1974 Copenhagen, Denmark Parallel multicenter | Vehicle Tretinoin Motretinide 2, 4, 8 | n=257 | Mild/mod | Overall change/physician Reduction in application due to side effects Side effects Total lesions change | ↓ Arms not comparable. | Retinoic acid the most potent, but motretinide better tolerated.
#61 Christiansen, 1974 Aarhus, Denmark Parallel multicenter | Motretinide Vehicle 2, 4, 6, 8 | n=19 female 22 male 7 Age 18.5 y | Can't say | Comedones change (count) Local reactions Total lesions change (count) | ↓ Major losses to followup. Arms not comparable. Execution not as designed. | Motretinide was superior to placebo.
#62 Chu, 1997 London, UK Parallel | Zinc + erythromycin Benzoyl peroxide + erythromycin 2, 4, 6, 8, 10 | n=72 Age 24.0 y | Mod | Adverse effects Clinical assessment/physician (score) Comedones change (median %) Improved by 50% or more Inflammatory change (count/median) | ↓ Patient not blinded. | Benzoyl peroxide 5% + erythromycin 3% was superior to erythromycin + zinc 1.2%.
#63 Clucas, 1997 Sophia Antipolis, France Parallel multicountry | Tretinoin Adapalene 2, 4, 8, 12 | n=591 female 276 male 317 Age 12.0-30 y | Mod/sev | Adverse reaction Discontinuation due to side effects | ↑ Randomized. Specific population. ↓ Patient not blinded. Enroller not blinded. Major losses to followup. Outcome assessor not blinded. Arms not comparable. | Adapalene 1% was better tolerated than tretinoin .025%.
#64 Cochran, 1985 Houston, USA Parallel | Vehicle Zinc 3, 6, 9, 12 | n=30 Age 16.0-30 y | Mild/mod | Irritation (score) Severity (Michaelsson) | ↓ Not randomized. Major losses to followup. Arms not comparable. | Topical zinc therapy alone produced no significant benefit.
#66 Colver, 1988 Oxford, UK Parallel | Cyproterone + ethinyl estradiol (0.05) Cyproterone + ethinyl estradiol (0.035) 8, 12, 24, 36 | n=96 female 78 male 0 Age 16.0-35 y | Can't say | Back severity Chest severity Face severity Severity change/patient (vas) Side effects | ↓ Not randomized. | Cyproterone-ethinyl estradiol-35 and cyproterone-ethinyl estradiol-50 were equally effective.
#69 Cornbleet, 1961 Chicago, USA Parallel | Topical treatment Tetracycline 48-78 (unspecified) | n=68 female 27 male 41 Age 19.0 y | Can't say | Improvement Side effects | ↓ Patient not blinded. Enroller not blinded. Major losses to followup. Outcome assessor not blinded. | Systemic tetracycline was better than topical treatment.
#70 Cornbleet, 1964 Chicago, USA Parallel | Tetracycline Demethylchortetracycline 4-22 (unspecified) | n=100 female 59 male 41 Age 21.3 y | Can't say | Overall change/physician Relapse Side effects | ↑ Randomized. Data show patient blinded. Data shows enroller blinded. No losses to followup. ↓ Outcome assessor not blinded. | Demethylchlorotetracycline was superior to tetracycline.
#71 Crounse, 1965 Miami, USA Cross-over matched | Tetracycline hydrochloride Demethylchlortetracycline Vehicle 4, 8, 12 | n=150 female 99 male 51 | Can't say | Severity change Side effects | | Antibiotics were not superior to vehicle.
#72 Cullen, 1976 Gainesville, USA Parallel | Tetracycline Minocycline 19 | n=100 female 73 male 27 Age 20.0 y | Mod/sev | Comedones (count) Cysts (count) Papules (count) Pustules (count) Side effects | ↑ Data shows enroller blinded. Data shows outcome assessor blinded. | Minocycline was as effective as tetracycline.
#74 Cunliffe, 1979 Leeds, UK Parallel | Zinc sulfate/citrate complex Tetracycline 4, 8, 12 | n=48 | Mod | Nodules (count) Non-inflammatory (count) Overall change/patient (vas) Papules (count) Pustules (count) Severity (Burton) | ↓ Patient not blinded. Enroller not blinded. Arms not comparable. Execution not as designed. | Tetracycline was superior to zinc complex in mild/severe acne.
#75 Cunliffe, 1980 Leeds, UK Parallel matched | Benzoyl peroxide Chloramphenicol + hydrocortisone + sulfur 4, 8, 12 | n=48 female 24 male 24 Age 15.0-17 y | Mod | Erythema Inflammatory (count) Non-inflammatory (count) Overall assessment/patient (vas) Scaling Severity (Leeds) | ↑ No losses to followup. ↓ Not randomized. | Chloramphenicol and benzoyl peroxide 5% were equally effective.
#76 Cunliffe, 1981 Leeds, UK Parallel matched | Benzoyl peroxide (lotion) Benzoyl peroxide (gel) 4, 8 | n=48 female 28 male 20 | Mod | Erythema Inflammatory (count) Non-inflammatory (count) Overall change/patient (% improvement) Scaling Severity (Pillsbury) | ↓ Major losses to followup. | Benzoyl peroxide gel and lotion were equally effective.
#77 Cunliffe, 1989 Leeds, UK Parallel matched | Azelaic acid Placebo 8, 12 | n=40 female 14 male 26 | Can't say | Inflammatory change (%) Local side effects Non-inflammatory change (%) | ↑ Randomized. ↓ Major losses to followup. Inconsistent ascertainment across arms. Arms not comparable. | 20% azelaic acid can be used as monotherapy for papulo-pustular acne.
#78 Cunliffe, 1997 Montpellier, France Parallel multicountry | Tretinoin Adapalene (0.03%) Adapalene (0.1%) 0, 1, 2, 4, 8, 12 | n=89 Age 12.0-30 y | Mild/mod/sev | Inflammatory (count) Non-inflammatory (count) Severity (Leeds) Total lesions change (%) | ↑ Randomized. Data shows enroller blinded. Data shows outcome assessor blinded. ↓ Major losses to followup. Arms not comparable. | Adapalene 0.1% and tretinoin were equally effective; adapalene had fewer side effects.
#80 Cunliffe, 1997 Leeds, UK Parallel multicountry | Tretinoin Adapalene 2, 4, 8, 12 | n=268 female 125 male 143 Age 19.5 y | Can't say | Burning Dryness Inflammatory change (%) Non-inflammatory change (%) Scaling | ↑ Randomized. Data shows enroller blinded. Data shows outcome assessor blinded. | Adapalene was as effective as tretinoin and had superior skin safety results.
#82 Danto, 1966 Vancover, Canada Parallel multicenter | Benzoyl peroxide + sulfur Sulfur 2 | n=113 female 59 male 54 Age 12.0-40 y | Mild/mod/sev | Overall change/physician Skin irritation | ↑ Data show patient blinded. Data shows enroller blinded. ↓ Arms not comparable. | Benzoyl peroxide plus sulphur was better than sulphur alone.
#84 De Bersaques, 1972 Ghent, Belgium Parallel | Salicylic acid + resorcinol + sulfur Tretinoin (.05%) Tretinoin (.02%) 2, 7 | n=60 | Can't say | Irritation Overall change/physician | ↓ Patient not blinded. Enroller not blinded. Major losses to followup. Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. Execution not as designed. | Vitamin A acid (tretinoin) is no cure-all.
#85 Degreef, 1982 Louvain, Belgium Parallel | Benzoyl peroxide Miconazole + benzoyl peroxide 4, 8, 12 | n=105 female 49 male 56 Age 12.0-24 y | Mod | Comedones (count) Overall change/patient Overall change/physician Severity change (score shift) Side effects | ↑ Randomized. No losses to followup. | Combination of miconazole + benzoyl peroxide was more effective therapy benzoyl peroxide alone.
#86 Delaney, 1959 Detriot, USA Parallel | Polythionate + quaternary ammonia complex of polythionate Polythionate Unspecified | n=72 female 46 male 26 Age 11.5-35 y | Can't say | Post-therapy overall change Side effects | ↓ Patient not blinded. Enroller not blinded. Major losses to followup. Outcome assessor not blinded. Arms not comparable. | Two preparations of polythionate produced benefits in patients with mild to severe acne.
#87 Dieben, 1994 Oss, The Netherlands Parallel multicountry | Cyproterone + ethinyl estradiol (0.035) Desogestrel + ethinyl estradiol 16 | n=183 female 183 male 0 Age 18.0-35 y | Mild | Comedones change (count/median) Papules change (count/median) Pustules change (count/median) Severity (Leeds) Severity change (Dieben/median) | ↓ Major losses to followup. | Cyproterone + ethinyl estradiol had a similar effect on mild to moderate acne.
#89 Dobson, 1980 Buffalo, USA Parallel multicenter | Erythromycin Vehicle 2, 4, 8, 10, 12 | n=253 female 161 male 93 | Mod/sev | Closed comedones change (%) Open comedones change (%) Overall change/physician Papules change (%) Pustules change (%) Skin reaction Total lesions change (%) Withdrawals | ↓ Major losses to followup. | Erythromycin base 1.5% liquid is effective.
#90 Dominguez, 1998 Mexico City, Mexico Parallel | Tretinoin Isotretinoin 2, 4, 8, 12 | n=30 female 18 male 12 Age 13.0-30 y | Mod | Comedones (count) Inflammatory (count) Irritation Stinging, erythema, desquamation | ↑ No losses to followup. ↓ Patient not blinded. Enroller not blinded. | Isotretinoin and tretinoin had a similar effect.
#91 Dreno, 1989 France Parallel multicenter | Zinc Placebo 4, 8 | n=66 female 27 male 39 Age 22.0±7.0 y | Mod | Abdominal pain Inflammatory severity (Dreno) Nausea Severity/patient Severity/photo | ↑ No losses to followup. ↓ Inconsistent ascertainment across arms. Arms not comparable. | Oral zinc gluconate at a low dose showed significantly better results than placebo in the treatment of in the treatment of inflammatory acne.
#92 Dunlap, 1998 Tucson, USA Parallel split face | Adapalene-immediate Adapalene-delayed 2 | n=25 female 36 male 14 Age 19.4±6.9 y | Mild/mod | Dryness (score) Erythema (score) | ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. | Adapalene 0.1% was well tolerated, even when applied immediately after washing.
#93 Dunlap, 1998 USA Parallel split face multicenter | Adapalene Tretinoin 1, 2, 3, 4 | n=100 female 96 male 104 Age 18.5 y | Mild/mod | Desquamation Dryness (score) Erythema (score) Inter-treatment preference Intolerance Local reactions/Dryness (score) Stinging/burning Total adverse skin symptom (score) Total adverse skin symptoms (score) | ↑ Randomized. No losses to followup. ↓ Patient not blinded. | Majority of patients prefer 0.1% adapalene gel over tretinoin 0.025% cream. Adapalene causes less skin irritation.
#94 Dunlop, 1995 Camperdown, Australia Parallel | Benzoyl peroxide Isolutrol 2, 4, 8, 12 | n=70 female 26 male 44 Age 18.6 y | Mild/mod | Burning Dryness Erythema Inflammatory (count) Non-inflammatory (count) Pruritis Scaling | ↓ Major losses to followup. | Benzoyl peroxide and isolutrol were both effective at reducing inflamed lesions. Isolutrol was not effective for non-inflamed lesions. Isolutrol produced fewer side effects.
#95 Eady, 1996 Leeds, UK Parallel | Vehicle Salicylic acid 4, 8, 12 | n=114 female 28 male 86 Age 16.0-25 y | Mild/mod | Inflammatory (count) Non-inflammatory (count) Overall change/patient (scale) Severity (Leeds) Total lesions (count) | | 2% salicylic acid has a significant effect on non-inflammatory lesions at 8 to 12 weeks and on inflammatory lesions at 12 weeks, with few side effects.
#97 Ede, 1973 Cincinnati, USA Parallel | Benzoyl peroxide + chlorhydroxyquinoline Benzoyl peroxide + chlorhydroxyquinoline + hydrocortisone Vehicle Benzoyl peroxide 2, 4 | n=196 Age 14.0-24 y | Mild/mod | Overall change/investigator Total lesions change (%) | ↑ Randomized. No losses to followup. | Benzoyl peroxide alone, in combination with chlorhydoxyquinoline alone or with hydrocortisone were all clinically superior to placebo. Loroxide HC^®^ demonstrated the most rapid benefit.
#98 Elbaum, 1988 Stanford, USA Parallel | Isotretinoin Tretinoin 2, 4, 8, 12 | n=18 | Can't say | Comedones change Comedones change (%) Inflammatory change (%) Total lesions change (%) | ↓ Arms not comparable. | Tretinoin and isotretinoin had similar efficacy.
#99 Ellis, 1988 Ann Arbor, USA Parallel | Clindamycin phosphate (lotion) Clindamycin phosphate (gel) Placebo 3, 6, 9, 12 | n=135 Age 13.0-35 y | Mod | Papules (count) Pustules (count) | ↓ Patient not blinded. Enroller not blinded. | Clindamycin solution and gel were effective.
#100 Ellis, 1998 USA Parallel multicenter | Tretinoin Adapalene 2, 4, 8, 12 | n=297 female 145 male 152 | Mod | Comedones change (count) Dose regime altered Inflammatory (count) Inflammatory change (%) Non-inflammatory (count) Non-inflammatory change (%) Severity (Leeds) Side effects Total lesions change (%) | ↑ Specific population. ↓ Patient not blinded. Major losses to followup. | Both adapalene and tretinoin were effective. Adapalene was more useful than tretinoin for treating open comedones. Side effects were similar.
#101 Elstein, 1981 Los Angeles, USA Parallel | Vehicle Sulfurated lime 2, 4, 7, 10 | n=59 Age 13.0-30 y | Mod | Comedones (count) Erythema Papules (count) Peeling Pustules (count) Severity change | | Sulphurated lime produced faster and greater improvement with significant reduction in papule counts compared to vehicle. Clay mask system eliminates odor and staining associated with Vleminckx's solution^®^.
#102 Ereaux, 1965 Montreal, Canada Parallel | Methyl prednisolone + neomycin + sulfur Vehicle Unspecified | n=134 | Can't say | Overall change | ↑ Randomized. Data show patient blinded. Data shows enroller blinded. ↓ Major losses to followup. Arms not comparable. | Methylprednisolone/neomycin/sulphur was effective for early and late stages of acne vulgaris.
#103 Erkkola, 1990 Turku, Finland Parallel multicenter | Cyproterone + ethinyl estradiol (0.035) Desogestrel + ethinyl estradiol 12, 32 | n=162 female 162 male 0 Age 20.0-40 y | Can't say | Back improvement Chest improvement Complete healing Face improvement Side effects | ↓ Patient not blinded. Enroller not blinded. Major losses to followup. Outcome assessor not blinded. | Cyproterone produced greater improvement for facial acne than desogestrel.
#106 Farrell, 1980 Iwoa city, USA Parallel | Isotretinoin (1.0) Isotretinoin (0.1) Isotretinoin (0.5) 1, 2, 3, 4, 5, 6, 7, 8, 10, 12; post-therapy:2, 4, 6, 8 | n=16 female 0 male 16 Age 16.0-31 y | Sev | Cheilitis duration (%) Cystic change (%) Cystic change post-treatment (%) Cystic diameter change (%) Cystic diameter change post-treatment Desquamation duration (week) Pruritus duration (weeks) | Randomized. Data show patient blinded. Data shows enroller blinded. ↓ Arms not comparable. | No significant difference is efficacy were noted between the groups.
#108 Feucht, 1980 Augusta, USA Parallel | Erythromycin + zinc (gel)+ Placebo (oral) Erythromycin + zinc (liquid) + placebo (oral) Tetracycline (oral) + placebo (topical) Placebo (topical) + placebo (oral) 2, 4, 6, 8, 10 | n=149 female 0 male 149 Age 18.0-26 y | Mild/mod/sev | Medication used (mg/kg) Papules change (%) Severity change (Cook %) Severity change (Cook) | Randomized. Data show patient blinded. Data shows outcome assessor blinded. Local population. | Erythromycin/zinc gel or liquid are as effective as oral tetracycline.
#109 Flanders, 1985 Athens, USA Parallel | Benzoyl peroxide (contingent contract) Benzoyl peroxide (non-contingent contract) Benzoyl peroxide (self monitoring) Untreated 12 | n=42 female 34 male 8 | Mod | Severity (Cook) Total lesions (count) | ↓ Patient not blinded. Enroller not blinded. Major losses to followup. Arms not comparable. | Methods that monitor compliance improve acne outcomes.
#110 Flinn, 1961 Madison, USA Parallel | Vehicle Tolbutamide 2, 4, 6, 8, 10, 12 | n=30 | Mod/sev | Overall change/patient Overall change/physician Severity/photo | ↑ Data shows outcome assessor blinded. ↓ Not randomized. Major losses to followup. Arms not comparable. | Tolbutanide was no better than placebo.
#111 Fluckiger, 1988 Basel, Switzerland Parallel | Benzoyl peroxide + miconazole Benzoyl peroxide 4, 8, 12 | n=52 female 26 male 26 Age 18.0 y | Mod/sev | Comedones (count) Irritation Irritation [female] Irritation [females] Irritation [male] Papules (count) Pustules (count) Total lesions (count) Total lesions change (%) Total lesions change [female] (%) Total lesions change [male] (%) | ↓ Patient not blinded. Major losses to followup. | Benzoyl peroxide and benzoyl peroxide + miconazole were equally effective. Benzoyl peroxide + miconazole was more effective in women and was better tolerated.
#114 Franz, 1978 Hamburg, Germany Parallel | Triclosan + propylene phenoxetol Triclosan Vehicle −4, 0, 4, 8 | n=72 female 0 male 72 Age 18.0-22 y | Mild/mod | Inflammatory (adjusted count) Inflammatory (count) Inflammatory (score) Non-inflammatory (count) Overall change/patient (vas) | ↓ Major losses to followup. | Topical triclosan combined with topical acne creams was more effective than acne creams alone.
#115 Fraser, 1980 Aberdeen, UK Parallel multicenter | Hydrocortisone + sulfur Chloramphenicol + hydrocortisone + sulfur 4, 8, 12 | n=37 female 25 male 12 | Can't say | Local reactions Overall change/patient Overall change/physician Severity change (Fraser %) | ↑ Randomized. | Both preparations produced comparable decreases in number of lesions.
#117 Fugere, 1990 Montreal, Canada Parallel multicenter | Cyproterone + ethinyl estradiol (0.035) Cyproterone + ethinyl estradiol (0.05) 24, 48 | n=73 female 73 male 0 Age 23.0±3.3 y | Mod/sev | Comedones severity (Cook) Macules score (Cook) Papules score (Cook) Papules time (Cook) Severity (Cook) | ↓ Major losses to followup. | Both cyproterone-ethinyl estradiol-35 and cyproterone-ethinyl estradiol-50 produced improvement;the lower estrogen dose was as effective as the higher dose.
#118 Fyrand, 1986 Norway Parallel split face | Benzoyl peroxide (alcohol) Benzoyl peroxide (water) 4, 8 | n=49 female 64 male 34 Age 14.0-44 y | Can't say | Burning Closed comedones change (%) Cysts change (%) Erythema (patient) Erythema (physician) Open comedones change (%) Papules change (%) Pustules change (%) Scaling (patient) Scaling (physician) Stinging | | Water-based benzoyl peroxide produced less irritation than alcohol based benzoyl peroxide.
#119 Galvin, 1998 USA Parallel split face | Petrolatum Tretinoin (0.025% cream) Tretinoin (0.01% gel) Tretinoin (0.025% gel) Tretinoin (0.05% cream) Tretinoin (0.1% cream) Adapalene 1-21days (unspecified) | n=28 female 25 male 3 Age 22.0-72 y | Can't say | Discontinuation due to side effects Irritation (score) | ↑ No losses to followup. ↓ Patient not blinded. | Adapalene was better tolerated than tretinoin.
#120 Galvin, 1998 USA Parallel split face | Petrolatum Tretinoin (0.025% cream) Tretinoin (0.1% gel) Tretinoin (0.05% cream) Tretinoin (0.1% cream) Adapalene 1-21 days (unspecified) | n=27 female 20 male 7 Age 22.0-72 y | Can't say | Discontinuation due to side effects Irritation (score) Local reactions/Irritation (Cumulative score) | ↑ No losses to followup. ↓ Patient not blinded. | Adapalene produced less irritation than any concentration of tretinoin.
#121 Gamborg-Nielsen, 1991 Varberg, Sweden Parallel | Benzoyl peroxide + metronidazole Vehicle 6 | n=43 female 24 male 19 Age 19.0 y | Mod/sev | Overall change/patient Severity change/photo | ↑ No losses to followup. ↓ Inconsistent ascertainment across arms. Arms not comparable. | Benzoyl peroxide + metronidazole was superior to placebo.
#122 Gamborg-Nielsen, 1991 Varberg, Sweden Parallel | Benzoyl peroxide Benzoyl peroxide + metronidazole 6 | n=60 female 33 male 27 Age 24.0 y | Mod/sev | Overall change/patient Overall change/physician Severity change/photo | ↑ No losses to followup. ↓ Patient not blinded. Inconsistent ascertainment across arms. Arms not comparable. | Benzoyl peroxide + metronidazole was superior to benzoyl peroxide alone.
#123 Gamborg-Nielsen, 1991 Varberg, Sweden Parallel | Oxytetracycline + vehicle Benzoyl peroxide + metronidazole + placebo 6 | n=52 female 30 male 22 Age 26.0 y | Mod/sev | Overall change/patient Overall change/physician Severity change/photo | ↓ Inconsistent ascertainment across arms. Arms not comparable. | Benzoyl peroxide + metronidazole was comparable to oxytetracycline.
#125 Gammon, 1986 Chapel Hill, USA Parallel multicenter | Tetracycline + placebo Erythromycin + placebo 2, 4, 8, 12 | n=178 female 87 male 91 | Mild/mod | Closed comedones change (%) Open comedones change (%) Overall change/patient Papules change (%) Pustules change (%) Side effects | ↑ Randomized. | Tetracycline and erthromycin both reduced acne severity, but the reduction was faster in the tetracycline group for closed comedones.
#126 Gandola, 1976 Como, Italy Parallel multicenter | Placebo + cotrimoxazole Sulfur-resorcinol + cotrimoxazole Tretinoin + cotrimoxazole 2, 3, 4, 5, 6, 7, 8 | n=211 female 146 male 65 Age 19.3 y | Can't say | Comedones change (count) Desquamation Erythema Papules change (count) Pustules change (count) Severity change (severity) | ↑ General population. ↓ Patient not blinded. Enroller not blinded. Major losses to followup. Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. | With each in combination with cotrimoxazole, retinoic acid was more effective than sulphur-resorcinol and placebo; sulphur-resorcinol was more effective than placebo.
#127 Geiger, 1996 Geneva, Switzerland Parallel matched multicountry | Alitretinoin Isotretinoin 2, 4 | n=26 female 0 male 26 Age 17.0-40 y | Can't say | Abdominal pain/diarrhea Dry eyes/conjunctivitis Dry mouth Dry nose Dry skin Dryness/cheilitis Headache Increased appetite Pruritis Red/scaling face Skin fragility | ↑ No losses to followup. ↓ Inconsistent ascertainment across arms. Outcome assessor not blinded. | All subjects had muco-cutaneous reactions; other side effects were reported to a greater extent with alitretinoin.
#128 Gibson, 1982 London, UK Parallel | Oxytetracycline Trimethoprim 4, 8 | n=45 | Mild | Active papules (sqrt count) Active pustules (sqrt count) Back severity (log Leeds) Chest severity (log Leeds) Face severity (log Leeds) Less active papules (sqrt count) Less active pustules (sqrt count) Overall change/patient Side effects | ↑ Randomized. Data shows enroller blinded. Data shows outcome assessor blinded. ↓ Patient not blinded. Execution not as designed. | Oxytetracycline and trimethoprim were both effective.
#130 Goldstein, 1982 Boston, USA Parallel multicenter | Isotretinoin Etretinate 2, 4, 6, 8;4, 8 post-therapy | n=56 female 0 male 56 Age 23.4 y | Sev | Mucous membrane side effects Nodulocystic change (%) Nodulocystic change post-therapy (%) Nodulocystic change post-treatment/face (%) Nodulocystic change/face (%) Skin side effects Systemic side effects | Data show patient blinded. Data shows enroller blinded. No losses to followup. Data shows outcome assessor blinded. ↓ Inconsistent ascertainment across arms. Arms not comparable. | Isotretinoin was significantly more effective than etretinate in reducing severe acne.
#131 Goltz, 1985 Minneapolis, USA Parallel | Clindamycin (lotion) Clindamycin (solution) 6, 12 | n=70 Age 22.0 y | Mod/sev | Burning Closed comedones (count) Diarrhea Dryness Erythema Itching Open comedones (count) Overall change/patient Overall change/physician Papules (count) Peeling Pustules (count) Severity (Goltz) | ↑ Randomized. Data shows enroller blinded. ↓ Patient not blinded. | Clindamycin lotion was less drying than solution and was equally effective.
#132 Goodfellow, 1984 London, UK Parallel | Placebo Spironolactone (200) Spironolactone (150) Spironolactone (100) Spironolactone (50) 12 | n=36 female 19 male 17 Age 24.0 y | Sev | Overall change Overall change/patient Overall change/photo | ↑ Randomized. Data shows enroller blinded. Data shows outcome assessor blinded. ↓ Major losses to followup. Arms not comparable. | The clinical response to spironolactone was dose dependent and was best at a dose of 1250-200mg.
#133 Goransson, 1978 Umea, Sweden Parallel | Placebo Zinc sulfur 3, 6 | n=59 female 22 male 27 Age 20.3 y | Mod | Comedones change (count) Overall change/patient Papules change (count) Pustules change (count) Severity change (% Michaelsson) Severity change (Michaelsson) | ↑ Randomized. Data show patient blinded. Data shows enroller blinded. Data shows outcome assessor blinded. | Zinc and placebo showed comparable effectiveness.
#136 Gratton, 1982 Montreal, Canada Parallel | Placebo Tetracycline + placebo Clindamycin + placebo 2, 4, 6, 8 | n=305 Age 18.0-35 y | Mod/sev | Overall change/patient Overall change/physician Papules (count) Pustules (count) Side effects | Specific population. | Both topical clindamycin phosphate and oral tetracycline hydrochloride were effective in moderate to severe acne.
#137 Greenwood, 1985 Leeds, UK Parallel | Tetracycline + placebo Cyproterone + ethinyl estradiol + placebo Cyproterone + ethinyl estradiol + tetracycline 8, 16, 24, 32 (= 4 post-therapy) | n=92 female 92 male 0 Age 16.0-30 y | Can't say | Face severity change (Leeds %) Inflammatory change (%) Non-inflammatory change (%) Post-therapy facial severity change (Leeds %) Post-therapy inflammatory change (%) Post-therapy non-inflammatory change (%) Post-therapy total severity change (Leeds %) Systemic reactions Total severity change (Leeds %) | ↑ Data shows outcome assessor blinded. ↓ Major losses to followup. Arms not comparable. | Cyproterone + ethinyl estradiol was as effective as tetracycline in treating women.
#138 Groot, 1963 Amsterdam, The Netherlands Parallel split face | Sham rays Grenz rays 7, 7-11, 12-14, 14-18 (unspecified) | n=40 female 42 male 38 Age 15.0-25 y | Can't say | Post-therapy overall state/observer | ↑ Randomized. ↓ Arms not comparable. | Treatment with Grenz rays is not recommended.
#139 Groot, 1963 Amsterdam, The Netherlands Parallel split face | Grenz rays Sham rays 7, 7-11, 12-14, 14-18 (unspecified) | n=33 | Can't say | Post-therapy overall state/observer | ↑ Randomized. ↓ Major losses to followup. Arms not comparable. | Treatment with Grenz rays is not recommended.
#140 Grosshans, 1998 Strasburg, France Parallel multicountry | Adapalene Tretinoin 1, 4, 12 | n=105 female 39 male 66 Age 20.5 y | Mild/mod | Inflammatory change (%) Non-inflammatory change (%) Severity [intention to treat] (Leeds) Severity [per protocol] (Leeds) Severity change [intention to treat] (Leeds %) Severity change [per protocol] (Leeds %) Side effects Withdrawal due to side effects | ↑ Randomized. ↓ Patient not blinded. | Adapalene 0.1% gel reduced inflammatory and total lesions more rapidly than tretinoin 0.025% gel and was better tolerated.
#141 Gruber, 1998 Vienna, Austria Parallel | Vehicle Cyproterone (topical) Cyproterone + ethinyl estradiol (0.035) 4, 8, 12 | n=45 female 45 male 0 Age 30.3 y | Mild/mod | Face severity (Leeds) Face severity change (Leeds) Total lesions (count) Total lesions change (count) | ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. | Topical cyproterone acetate and oral cyproterone + ethinyl estradiol were equally effective.
#142 Guerrier, 1980 Northampton, UK Parallel | Chloramphenicol + sulfur Chloramphenicol + hydrocortisone + sulfur 2, 4, 8, 12 | n=50 female 29 male 15 | Mild/mod | Overall change/patient Overall change/physician Severity (score) Total lesions change (%) | ↓ Arms not comparable. | Chloramphenicol/sulphur with or without hydrocortisone was effective for mild to moderate acne.
#143 Guin, 1979 USA Parallel split face | Clindamycin hydrochloride Clindamycin phosphate 2+ (unspecified) | n=42 | Sev | Nodules (count) Papules (count) Pustules (count) | ↑ Data show patient blinded. Data shows enroller blinded. Data shows outcome assessor blinded. ↓ Major losses to followup. Arms not comparable. | Clindamycin hydrochloride was slightly better than clindamycin phosphate.
#144 Guin, 1981 Indianapolis, USA Parallel | Vehicle Clindamycin | n=31 | Mod/sev | Overall change/physician Side effects | No losses to followup. ↓ Not randomized. | The study was too small to demonstrate a difference.
#145 Gunning, 1994 Ames, USA Parallel | Retinyl beta-glucuronide Vehicle 2, 4, 8, 12 | n=29 female 0 male 29 Age 20.4 y | Mild/mod | Adverse reaction Efficacy to initial (Spearman) Inflammatory (count/median) Inflammatory change (ratio to initial) Non-inflammatory (count/median) Non-inflammatory change (ratio to initial) Non-responders Overall change/physician (score) Total lesions (count/median) Total lesions (ratio to initial) Total lesions change (ratio to initial) | ↑ No losses to followup. | RBG reduced both inflammatory and non-inflammatory lesions.
#146 Gunning, 1994 Ames, USA Parallel | Retinyl beta-glucuronide Tretinoin 2, 4, 6, 8, 14, 19, 28 | n=15 Age 22.5 y | Mild/mod | Adverse reaction Inflammatory (count/median) Inflammatory lesion (ration to initial) Non-inflammatory (count/median) Non-inflammatory change (ratio to initial) Non-responders Overall change/physician (score) Total lesions (count/median) Total lesions change (ratio to initial) | ↑ No losses to followup. ↓ Outcome assessor not blinded. | RBG and tretinoin were equally effective for mild to moderate acne.
#147 Habbema, 1989 Rotterdam, The Netherlands Parallel multicountry | Erythromycin Erythromycin + zinc 2, 4, 8, 12 | n=122 | Mod | Comedones change (%) Comedones change (count) Inflammatory change (%) Local side effects Macules (count) Nodules (count) Severity (Cook) | ↑ Data shows enroller blinded. | Erythromycin/zinc lotion was more effective than 2% erythromycin in reducing number of acne lesions and severity grade of acne.
#149 Handojo, 1979 Surabaya, Indonesia Parallel | Benzoyl peroxide (10%) Benzoyl peroxide (5%) Tretinoin Tretinoin + benzoyl peroxide (10%) Tretinoin + benzoyl peroxide (5%) 10 | n=250 female 202 male 48 Age 11.0-39 y | Mild/mod/sev | Inflammatory changes (Witkowski discretized %) Non-inflammatory change (Witkowski discretized %) Overall change (Witkowski discretized %) Overall change (Witkowski discretized %) Side effects/Withdrawal Time to favorable status (Mean weeks) | No losses to followup. ↓ Patient not blinded. Enroller not blinded. Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. | Tretinoin + benzoyl peroxide is the treatment of choice.
#151 Hansted, 1985 Copenhagen, Denmark Parallel | Vehicle Fusidin 2, 4, 6 | n=79 female 16 male 54 Age 19.0 y | Mild/mod | Comedones (count) Inflammatory (count) Side effects | ↓ Inconsistent ascertainment across arms. | Fusidin cream was superior to placebo cream in mild to moderate acne.
#152 Harcup, 1980 Malvera, UK Parallel matched | Oxytetracycline Co-trimoxazole 4, 8, 12 | n=16 female 10 male 6 Age 15.5 y | Mild/mod/sev | Inter-treatment severity comparison Overall change/matched (vas) Severity (Leeds) Severity change/photo Side effects | ↑ No losses to followup. Local population. | Trimethoprim + sulphamethoxazole was more effective than oxytetracycline.
#155 Harrison, 1988 Lancaster, UK Parallel | Minocyclin Doxycycline 12 | n=43 female 21 male 22 Age 20.0 y | Mild/mod/sev | Cysts change (%) Nodules change (%) Papules changes (%) Pustules change (%) Severity change (% Wright) Side effects Total lesions (%) | ↓ Patient not blinded. Major losses to followup. | Doxycycline is just as effective as minocycline.
#156 Hatwal, 1988 Varanari, India Parallel | Spironolactone [women] Spironolactone [men] Cimetidine [men] Cimetidine [women] 12 | n=50 female 31 male 19 Age 14.0-25 y | Mod/sev | Severity (Michaelsson) | ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. Arms not comparable. | Acne severity decreased with spironolactone and cimetidone, but more so with spironolactone.
#157 Hellgren, 1980 Irondheim, Norway Parallel matched split face | Vehicle Erythromycin Unspecified | n=29 female 16 male 12 Age 15.0-34 y | Mod/sev | Overall comparison Severity change (Plewig) | Data show patient blinded. No losses to followup. Data shows outcome assessor blinded.
#158 Henderson, 1995 Raritan, USA Parallel | Erythromycin Clindamycin phosphate 2, 4, 8 | n=120 female 56 male 49 Age 21.3±1.0 y | Mod | Adverse reactions Comedones (count) Comedones change (%) Cysts change (%) Inflammatory (count) Inflammatory change (%) Overall change/investigator Total lesions change (%) Total lesions change (count) | ↑ Data shows outcome assessor blinded. ↓ Patient not blinded. Enroller not blinded. | Topical erythromycin was more effective than topical clindamycin phosphate for inflammatory acne. Erythromycin pledgets were more convenient, sanitary, and easier to use than clindamycin lotion.
#160 Hersle, 1972 Gothenburg, Sweden Cross-over matched | Co-trimoxazole Vehicle 5, 10 | n=42 female 14 male 70 Age 13.0-30 y | Can't say | Severity change [phase i] (Witkowski %) Severity change [phase ii] (Witkowski %) | ↑ No losses to followup. ↓ Inconsistent ascertainment across arms. Arms not comparable. | Trimethoprim + sulphamethoxazole was superior to vehicle.
#161 Hersle, 1976 Gothenburg, Sweden Cross-over | Placebo Minocycline 5 | n=43 female 14 male 29 Age 14.0-34 y | Can't say | Severity (Witkowski) Severity change [phase ii] (group %) Side effects | ↑ Data shows outcome assessor blinded. | Minocycline was superior to placebo.
#162 Hicks, 1962 Miami, USA Parallel | Placebo Demethylchlortetracycline 2-18 (unspecified) | n=37 | Mod/sev | Adverse effects Severity change | ↑ No losses to followup. ↓ Inconsistent ascertainment across arms. Arms not comparable. | Demethylchlortetracycline was effective. Photosensitivity was the most common side effect.
#163 Hillstrom, 1977 Gavle, Sweden Parallel multicenter | Placebo Zinc sulfate 4, 8, 12 | n=112 Age 18.4 y | Mod/sev | Overall change/patient Overall change/physician Side effects Withdrawal due to side effects | | Zinc treatment was better than placebo.
#164 Hjorth, 1984 Rodovre, Denmark Parallel | Meclocycline sulfosalicylate + placebo Tetracycline + vehicle 4, 8 | n=60 female 34 male 26 Age 20.0 y | Mild/mod | Closed comedones change (%) Cysts change (%) Open comedones change (%) Papules change (%) Pustules change (%) Total lesions change (%) | ↑ Randomized. No losses to followup. ↓ Inconsistent ascertainment across arms. Arms not comparable. | Topical meclocycline sulfosalicylate was an effective and safe alternative to systemic tetracycline.
#165 Hjorth, 1985 Rodovre, Denmark Parallel split face | Vehicle Aluminum chloride 2, 4, 8 | n=25 female 36 male 14 Age 23.0 y | Mild/mod | Overall change | ↑ Data show patient blinded. | Topical 6.25% aluminum in anhydrous alcohol had a good clinical effect.
#166 Hjorth, 1989 Copenhagen, Denmark Parallel multicenter | Azelaic acid + placebo Tetracycline hydrochloride 12, 20 | n=333 female 155 male 178 | Mild/mod | Overall change/physician Total lesions (count/median) | ↑ Randomized. ↓ Major losses to followup. Inconsistent ascertainment across arms. Arms not comparable. Execution not as designed. | 20% azelaic acid cream was an effective topical treatment for inflammatory acne.
#167 Hjorth, 1989 Copenhagen, Denmark Parallel multicenter | Tetracycline hydrochloride + placebo Azelaic acid + placebo 4, 8, 12, 16, 20, 24 | n=261 female 68 male 193 | Mod/sev | Inflammatory (count/median) Nodes+cysts (count/median) Overall change/patient | ↑ Randomized. ↓ Major losses to followup. Inconsistent ascertainment across arms. Arms not comparable. Execution not as designed. | 20% azelaic acid cream was an effective topical treatment for inflammatory acne.
#171 Hubbell, 1982 Lackland, USA Cross-over | Minocycline Tetracycline 3, 6, 9, 12, 15, 18, 21, 24 | n=104 female 27 male 22 Age 17.4 y | Mod/sev | Mild/mod local side effects Mild/mod systemic side effects Persistent severity reduction Severe side effects Severity change Severity reduction (cumulative %) Time to severity reduction (days) | ↓ Major losses to followup. Inconsistent ascertainment across arms. Outcome assessor not blinded. | No statistically significant difference between the two treatments.
#172 Hughes, 1983 Coral Gables, USA Parallel matched | Relaxation training + benzoyl peroxide + erythromycin Group therapy Benzoyl peroxide + erythromycin 4, 8 | n=30 female 24 male 6 Age 27.1±6.6 y | Mild/mod | Post-therapy severity (Cook) Severity (Cook) Severity difference/staff, patient Severity/patient (Cook) | ↑ Data shows enroller blinded. No losses to followup. Data shows outcome assessor blinded. | Biofeedback relaxation combined with cognitive imagery reduced acne severity.
#173 Hughes, 1992 Leeds, UK Parallel | Vehicle Benzoyl peroxide Isotretinoin 4, 8, 12 | n=77 female 31 male 46 Age 18.7 y | Mild/mod | Inflammatory (count) Local reactions I Local reactions II Non-inflammatory (count) Severity (Leeds) | ↑ Referral population. ↓ Arms not comparable. | Both topical benzoyl peroxide (5%) and topical isotretinoin (5%) were effective treatments for mild/moderate acne. Isotretinoin had a slower response rate for resolution of inflamed lesions.
#175 Hull, 1989 Leeds, UK Parallel split face | Vehicle Clobetasol 3 | n=11 female 14 male 8 Age 15.0-25 y | Mod | Inflammatory (count) Severity change | ↑ No losses to followup. ↓ Not randomized. Patient not blinded. Enroller not blinded. Inconsistent ascertainment across arms. Outcome assessor not blinded. Execution not as designed. | Clobetasol propionate did not significantly reduce the number of inflamed acne lesions.
#176 Hunt, 1992 Sydney, Australia Parallel | Vehicle Gluconolactone Benzoyl peroxide 2, 4, 8, 12 | n=150 female 65 male 70 Age 20.1 y | Mod/sev | Inflammatory change (%) Local effects Non-inflammatory change (%) Total lesions change (%) | ↓ Arms not comparable. | Topical gluconolactone as effective as benzoyl peroxide for inflamed and total lesions, and was better tolerated.
#177 Jaffe, 1989 UK Parallel multicenter | Vehicle Hydroxyquinoline + benzoyl peroxide + hydrocortisone Hydroxyquinoline + benzoyl peroxide Benzoyl peroxide 12 | n=107 | Can't say | Clinical assessed facial lesions Clinical assessment back lesions Clinical assessment chest lesions Face severity (Jaffe) Greasiness | ↑ Data show patient blinded. Data shows enroller blinded. Data shows outcome assessor blinded. | The combination cream better was superior.
#178 Jelinek, 1972 New York City, USA Cross-over | Hydrochlorthiazide Vehicle 4, 8 | n=42 female 42 male 0 | Can't say | Adverse reactions/No withdrawals Adverse reactions/Withdrawals Premenstrual change/patient [phase ii] Premenstrual overall change/patient [phase ii] Premenstrual overall change/physician [phase i] Premenstrual overall change/physician [phase ii] | ↓ Major losses to followup. | Hydrochlorothiazide was ineffective in premenstrual acne.
#179 Jelliffe, 1969 London, UK Parallel matched split face | Sham rays Grenz rays 16, 24 | n=40 | Can't say | Improvement | ↑ No losses to followup. ↓ Not randomized. Enroller not blinded. | Grenz rays had no effect.
#180 Jelliffe, 1969 London, UK Parallel matched split face | Sham rays Grenz rays 4, 7 | n=42 | Can't say | Severity change (group %) | ↑ No losses to followup. ↓ Not randomized. Enroller not blinded. | Grenz rays at 50 kV may be beneficial.
#184 Jones, 1981 Indianapolis, USA | Vehicle Erythromycin 3, 6, 9, 12 | n=175 female 88 male 68 Age 22.6±5.6 y | Mod | Burning-irritation Dryness Exudate Eye irritation Herpes simplex Inflammatory (group count) Oiliness Overall change/physician Pruritis Redness Scaling Side effects | ↑ Data shows outcome assessor blinded. Specific population. | 2% topical erythromycin improved moderate to severe acne, but some side effects were seen.
#185 Jones, 1983 Leeds, UK Parallel | Isotretinoin (1.0) Isotretinoin (0.5) Isotretinoin (0.1) 4, 8, 12, 16, 20, 24, 28, 32 | n=76 female 45 male 31 Age 24.3±6.2 y | Mod | Local reactions/Cheilitis severity Local reactions/Conjunctivitis Local reactions/Dermatitis severity Local reactions/Desquamation severity Non-inflammatory change (%) Post-therapy non-inflammatory change (%) Systemic reactions/Arthralgia Systemic reactions/Epistaxis severity Systemic reactions/Malaise | ↑ No losses to followup. ↓ Inconsistent ascertainment across arms. Execution not as designed. | Isotretinoin at 0.5 mg/kg was recommended over 0.1 or 1.0 mg/kg for initial treatment, balancing relapse rate and side effects.
#186 Katsambas, 1987 Athens, Greece Parallel | Tetracycline hydrochloride + placebo Clindamycin + placebo 3, 6, 9, 12 | n=44 female 42 male 2 Age 13.0-30 y | Mod | Closed comedones (count) Nodules (count) Open comedones (count) Papules (count) Pustules (count) Side effects | ↓ Major losses to followup. | Topical clindamycin was effective to treat moderate acne vulgaris.
#187 Katsambas, 1989 Athens, Greece Parallel | Vehicle Azelaic acid 4, 8, 12 | n=92 female 65 male 27 Age 19.0 y | Mod | Burning Comedones change (%) Erythema Inflammatory (count/median) Itching Overall change/physician Scaling | ↑ Randomized. ↓ Inconsistent ascertainment across arms. | Azelaic acid was a therapeutically active drug.
#188 Katsambas, 1989 Athens, Greece Parallel | Tretinoin Azelaic acid 20 | n=289 female 152 male 137 Age 17.5 y | Can't say | Comedones (count) Comedones (count/median) Erythema Overall change/physician Scaling | ↑ Randomized. ↓ Major losses to followup. Inconsistent ascertainment across arms. | 20% azelaic acid cream showed the same therapeutic benefit in comedonal acne as 0.05% tretinoin cream but caused side effects.
#189 Kern, 1962 Providence, USA Parallel | Placebo Gamma-globulin 6-48 (unspecified) | n=40 female 21 male 19 Age 15.0-30 y | Mod/sev | Overall change/physician Side effects | ↓ Major losses to followup. Inconsistent ascertainment across arms. Arms not comparable. | Gamma-globulin every two weeks was not useful in the management of moderate acne.
#190 King, 1982 Leeds, UK Parallel | Isotretinoin (0.1) Isotretinoin (1.0) Isotretinoin (0.5) 4, 8, 12, 16 | n=48 female 24 male 24 Age 25.0 y | Mild/mod/sev | Severity/face (king) | ↓ Major losses to followup. Arms not comparable. | No evidence of dose response.
#191 Kirton, 1967 UK Parallel split face | Proprietary formula (sulfur + salicylic acid + resorcinol) Placebo Komed^®^ (sulfur + salicylic acid + resorcinol) 16, end of study (up to 36) | n=51 female 38 male 13 Age 13.0-28 y | Mild/mod/sev | Overall change/physician | ↑ No losses to followup. Referral population. ↓ Arms not comparable. | Komed was an effective treatment.
#192 Knox, 1965 Houston, USA Parallel | Demethylchlortetracycline Placebo 3 | n=74 | Can't say | Overall change/physician | ↑ No losses to followup. ↓ Arms not comparable. | Systemic demethylchlortetracycline was effective in treating acne vulgaris.
#193 Knox, 1965 Houston, USA Cross-over | Placebo Demethylchlortetracycline 3, 7 | n=74 | Can't say | Overall change/physician, patient | ↑ No losses to followup. | Demethylchlortetracycline was better than placebo.
#194 Knutson, 1981 Sioux Falls, USA Parallel multicenter | Vehicle Meclocycline 2, 4, 8, 11 | n=134 | Mod/sev | Comedones (count) Inflammatory change Side effects | No losses to followup. Referral population. ↓ Not randomized. Inconsistent ascertainment across arms. | Meclocycline is effective and safe. Twice daily is as effective as once-daily, but perhaps achieves effect quicker.
#195 Knutson, 1981 Sioux Falls, USA Parallel multicenter | Vehicle Meclocycline 2, 5 | n=217 | Mod/sev | Adverse effects Inflammatory change (median %) | No losses to followup. Referral population. ↓ Not randomized. Inconsistent ascertainment across arms. | Meclocycline is safe and effective. Once daily administration is as effective, but longer time to reach maximal effect.
#197 Korting, 1995 Munich, Germany Parallel | Acidic syndet bar Soap 12 | n=114 female 47 male 67 Age 20.0±3.3 y | Mild | Inflammatory (count) Itching Non-inflammatory (count) Redness Scaling | ↑ Randomized. Data shows enroller blinded. ↓ Patient not blinded. Outcome assessor not blinded. | Acidic syndet lowerd the number of inflammatory acne lesions in acne-prone patients more than regular use of soap.
#198 Krishnan, 1976 Liecester, UK Parallel | Vehicle Tretinoin (0.025%) Tretinoin (0.05%) 12 | n=60 Age 18.0-21 y | Can't say | Clinical assessment Comedones (count) Papules (count) Pustules (count) Severity/patient (vas) Side effects | ↑ Data shows enroller blinded. No losses to followup. ↓ Inconsistent ascertainment across arms. Arms not comparable. | Topical tretinoin 0.05% and 0.025% were both better than placebo and about equally effective. There were fewer side effects with 0.025% tretinoin.
#199 Kuhlman, 1986 Louisville, USA Parallel | Vehicle Clindamycin phosphate 3, 6, 12 | n=45 Age 12.0-30 y | Mild/mod | Closed comedones (count) Dryness, peeling, erythema, burning and itching Nodes+cysts (count) Open comedones (count) Overall change/physician Papules (count) Pustules (count) Severe side effects | ↑ No losses to followup. ↓ Inconsistent ascertainment across arms. | Topical clindamycin was effective for moderate to severe acne and was well tolerated. [By the Combined Acne Severity Classification, these patients' acne is classified as “mild to moderate.”]
#201 Lane, 1969 Leeds, UK Parallel | Tetracycline Placebo 6, 12 | n=51 female 25 male 26 Age 18.0 y | Can't say | Clinical change (grouped) Clinical change/photo (grouped) Clinical improvement/photo (grouped) Severity change (Pillsbury modified) Side effects | ↑ Randomized. Data shows enroller blinded. Data shows outcome assessor blinded. Referral population. ↓ Arms not comparable. | Tetracycline was better than placebo for moderate acne. (Note that baseline data was not provided to document acne severity.)
#202 Langner, 1994 Warsaw, Poland Parallel | Vehicle Isotretinoin (0.05%) Isotretinoin (0.1%) 4, 8, 12 | n=82 | Mild/mod | Closed comedones (count) Papules (count) Side effects | | .01% and 0.05% istretinoin reduced acne grade, particulary closed comedones, more than placebo. 0.1% isotretinoin was better tolerated.
#204 Lassus, 1996 Helsinki, Finland Parallel | Silicic acid Vehicle 6 | n=30 female 19 male 11 Age 19.0 y | Mod | Comedones (count) Cysts (count) Papules (count) Pustules (count) | ↑ No losses to followup. ↓ Enroller not blinded. | Silicic acid was more effective than placebo.
#205 Lesher, 1985 Augusta, USA Parallel multicenter | Vehicle Erythromycin 2, 4, 8, 10, 12 | n=225 female 76 male 132 Age 18.6 y | Mild/mod | Erythema Inflammatory (count) Inflammatory (count) Peeling Severity (Cook) Severity change (Cook %) | ↑ Randomized. | 2% erythromycin was better than vehicle.
#206 Lester, 1985 Toronto, Canada Parallel | Tetracycline hydrochloride Isotretinoin 2, 4, 8, 12, 16, 20, 24, 35 | n=30 female 1 male 29 Age 25.4±6.5 y | Sev | Comedones+pustules (count) Cysts (count) Cysts diameters (mm) Integumentary side effects I Integumentary side effects II Integumentary side effects III Post-therapy back total lesions change Post-therapy chest total lesion change Post-therapy comedones+pustules (count) Post-therapy cyst diameters (mm) Post-therapy long term cyst (count) Systemic reactions Systemic reactions/Special senses | ↓ Enroller not blinded. Major losses to followup. | After 16 weeks treatment both isotretinoin and tetracycline produced similar improvement in patients with severe recalcitrant nodulocystic acne. 8 weeks after treatment, patients treated with isotretinoin continued to improve more than those treated with tetracycline.
#208 Leyden, 1987 Brooklyn, USA Parallel multicenter | Erythromycin Clindamycin phosphate 4, 8, 12 | n=109 female 50 male 52 Age 17.8 y | Mild/mod | Closed comedones change (count) Inflammatory change (count) Local tolerability Non-inflammatory change (count) Open comedones change (count) Overall change/patient Papules change (count) Pustules change (count) Severity change (% response) | ↓ Patient not blinded. | Topical erythromycin 2% gel was as effective as topical clindamycin phosphate 1% solution in reducing number solution in reducing number of lesions and in improving overall acne condition.
#211 Liden, 1980 Umea, Sweden Parallel | Placebo Zinc sulfate 3, 6 | n=59 female 22 male 32 Age 20.3 y | Mild/mod/sev | Severity change (Pillsbury %) | | Zinc had a weak but statistically significant effect.
#212 Lim, 1974 London, UK Parallel | Tetracycline hydrochloride Tetracycline (sustained release) 4, 8, 12 | n=55 female 23 male 16 Age 20.0 y | Can't say | Overall change/physician Side effects | ↑ Data shows outcome assessor blinded. ↓ Major losses to followup. Arms not comparable. | Sustained-release tetracycline (at half the standard dose of tetracycline) was as effective as treracycline hydrochloride.
#213 Lookingbill, 1992 Hershey, USA Parallel multicenter | Vehicle Inocoterone acetate 4, 8, 16 | n=153 female 0 male 153 | Mod | Comedones (count) Inflammatory (count) Local adverse reactions | ↑ Randomized. | Topical inocoterone acetate produced a modest clinical effect.
#214 Lookingbill, 1997 Hershey, USA Parallel multicenter | Vehicle Benzoyl peroxide Clindamycin Clindamycin + benzoyl peroxide 2, 5, 8, 11 | n=393 female 202 male 191 Age 18.5 y | Mod | Inflammatory change (%) Local side effects Non-inflammatory change (%) Overall change/physician | ↑ Randomized. Data shows enroller blinded. Data shows outcome assessor blinded. General population. ↓ Major losses to followup. Arms not comparable. | A combination was better than either component alone.
#215 Lowney, 1964 Philadelphia, USA Parallel matched split face | Comedone extraction (cheeks/forehead) Comedone extraction (forehead) 12 | n=20 female 4 male 16 Age 15.0-22 y | Can't say | Inflammatory change | ↑ No losses to followup. ↓ Not randomized. Patient not blinded. Enroller not blinded. Outcome assessor not blinded. | Comedones extraction was effective in superficial, but not cystic, acne. It was more effective on the forehead than the cheeks.
#216 Lowney, 1964 Philadelphia, USA Parallel matched split face | Comedone extraction (cheeks/forehead) Untreated Unspecified | n=12 female 3 male 9 Age 14.0-18 y | Can't say | Inflammatory change | ↑ No losses to followup. ↓ Not randomized. Patient not blinded. Enroller not blinded. Outcome assessor not blinded. | Comedones extraction was effective in superficial, but not cystic, acne. It was more effective on the forehead than the cheeks.
#217 Lucchina, 1996 Boston, USA Parallel | Clindamycin Vehicle 2, 4, 8, 12 | n=42 female 19 male 13 Age 13.0-31 y | Mod | Closed comedones (count) Open comedones (count) Papules (count) Pustules (count) Severity (Leeds) Severity/flash photo (Leeds) Severity/fluorescent photo-face+nose (Leeds) Severity/fluorescent photography Severity/fluorescent photo-nose (Leeds) | ↑ Data shows outcome assessor blinded. ↓ Patient not blinded. Enroller not blinded. Major losses to followup. | Clindamycin was more effective than placebo in a study using fluorescence photography.
#218 Lucky, 1997 Cinncinnati, USA Parallel multicenter | Norgestimate + ethinyl estradiol + inactive drug Placebo 4, 8, 12, 16, 20, 24, 25, 26 | n=257 female 231 Age 27.0 y | Mod | Closed comedones change (count) Comedones change (count) Inflammatory (count) Nodules change (count) Open comedones change (count) Overall change/investigator Overall change/patient Total lesions change (%) Total lesions change (count) | ↑ Randomized. Data shows outcome assessor blinded. Specific population. ↓ Major losses to followup. | Norgestimate-ethinyl estradiol use led to greater decreases in acne lesion counts and better global ratings than placebo in women with moderate acne
#219 Lucky, 1998 Cinncinnati, USA Parallel multicenter | Polyoprepolymer-2 Tretinoin Tretinoin + polyoprepolymer-2 2, 4, 8, 12 | n=344 female 135 male 136 Age 20.0±5.8 y | Mild/mod | Inflammatory change (%) Non-inflammatory change (%) Overall change/physician Side effects Total lesions change (%) | ↑ Data show patient blinded. Data shows enroller blinded. Referral population. | Tretinoin and tretinoin with polymer were equally efficacious and safe for mild-moderate acne.
#220 Lucky, 1998 Cinncinnati, USA Parallel multicenter | Vehicle Tretinoin (ethanol) Tretinoin (polyoprepolymer-2) 2, 4, 8, 12 | n=215 female 118 male 97 | Mild/mod | Adverse effect Adverse effects Any adverse outcome Dry skin Eruption Inflammatory change (%) Non-inflammatory change (%) Other skin symptoms Systemic adverse effects Total lesions change (%) | ↓ Arms not comparable. | Ethanol and polyprepolymer-2 gels containing 0.025% tretinoin had similar efficacy but polyoprepolymer-2 caused less peeling and drying.
#221 Lyons, 1978 San Antonio, USA Parallel multicenter | Benzoyl peroxide (alcohol) Benzoyl peroxide (acetone) Tretinoin 2, 4, 6, 8 | n=147 female 107 male 40 Age 18.7 y | Mod | Adverse reaction Comedones (count) Comedones change (%) Papules (count) Papules change (%) Pustules (count) Pustules change (%) Severity change | ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. | Benzoyl peroxide and tretinoin were equally effective.
#222 MacDonald, 1951 UK Parallel | Vehicle Staphylococcal toxoid 10, 24 | n=66 female 0 male 66 | Mild/mod/sev | Adverse reaction Overall change/patient Overall change/physician [mild] Overall change/physician [moderate] Overall change/physician [severe] | ↑ No losses to followup. Specific population. | Staphylococcal toxoid injection was efficacious in management of recalcitrant pustular acne.
#223 MacDonald, 1972 Glasgow, UK Cross-over matched | Placebo Co-trimoxazole 4 | n=40 Age 18.5 y | Can't say | Comedones change [phase i+ii] (count) Dizziness and headaches Pustules change [phase i+ii] (count) Red macular rash | ↑ Data show patient blinded. Data shows enroller blinded. Data shows outcome assessor blinded. | Trimethoprim-sulphamethoxazole was as effective as placebo.
#224 MacDonald, 1976 Manchester, UK Cross-over | Hydrocortisone + buttoxethyl nicotinate + chloramphenicol Vehicle 4, 10 | n=120 female 78 male 42 | Mild/mod/sev | Comedones reduction percentage change (%) Inter-group difference papule % change (%) Inter-group difference pustule % change (%) Side effects | ↑ Data show patient blinded. ↓ Enroller not blinded. Major losses to followup. Outcome assessor not blinded. | Topical mixture of sulphur chloramphenicol hydrocortisone and buttoxyl ethyl nicotinate was better than vehicle.
#225 Mango, 1996 Rome, Italy Parallel | Gestodene + ethinyl estradiol Desogestrel + ethinyl estradiol 12, 24, 36 | n=24 female 24 Age 24.0±3.7 y | Mild/mod | Severity (Pillsbury) Severity change (Pillsbury) Severity/arm (Pillsbury) Systemic adverse effects | ↓ Patient not blinded. Enroller not blinded. Major losses to followup. Outcome assessor not blinded. | Ethinyl estradiol desogestreland ethinyl estradiol-gestodene were effective in reducing acne.
#228 Mcguiness, 1965 Sussex, UK Parallel multicenter | Neomycin + methyl prednisolone Vehicle Aluminum chlorhydroxide + sulfur 4-6 (unspecified) | n=776 | Can't say | Overall change/physician | ↓ Major losses to followup. Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. Execution not as designed. | Neomycin + methylprednisolone was effective.
#229 McKenzie, 1981 Gainesville, USA Parallel split face | Ionax^®^ E-solve^®^ Clindamycin hydrochloride (Ionax^®^) Clindamycin hydrochloride (E-solve^®^) Clindamycin phosphate (Ionax^®^) Clindamycin phosphate (E-solve^®^) 4, 8, 12 | n=88 female 64 male 20 Age 20.3 y | Mod/sev | Inflammatory change (%) | ↑ Randomized. Local population. | The effectiveness of clindamycin compared with the hydroalcoholic products was not significantly greater.
#231 Mesquita Guimar 1989 Porto, Portugal Parallel | Benzoyl peroxide Benzoyl peroxide + miconazole 2, 4, 8 | n=20 Age 17.0±2.4 y | Mild/mod/sev | Comedones change (geometric mean) Exfoliation Inflammatory change (geometric mean) Overall assessment/patient Overall assessment/physician Pustular lesions Side effects | ↑ Randomized. No losses to followup. | Benzoyl peroxide + miconazole was better than benzoyl peroxide alone, particularly for inflammatory acne.
#232 Michaelsson, 1977 Uppsala, Sweden Parallel | Oxytetracycline Zinc sulfate 2, 4, 8, 12 | n=40 female 16 male 24 Age 15.0-29 y | Mod/sev | Comedones change (count) Comedones severity change (Michaelsson difference) Overall change/patient Overall change/physician Papules change (count) Papules severity change (Michaelsson difference) Pustules change (count) Pustules severity change (Michaelsson difference) Total severity change/photo (Michaelsson) | ↑ No losses to followup. | The effects of oral zinc and chlortetracycline were comparable in patients with moderate to severe acne.
#233 Michaelsson, 1977 Uppsala, Sweden Parallel | Zinc sulfate + Vitamin A palmitate Zinc sulfate Vitamin A palmitate Vehicle 2, 4, 6, 8, 12 | n=64 female 26 male 38 Age 13.0-25 y | Mod/sev | Severity change (Michaelsson %) Side effects | ↑ No losses to followup. ↓ Arms not comparable. | Zinc decreased the number of papules, pustules and infiltrates. There was no significant effect for Vitamin A.
#235 Milikan, 1976 Columbia, USA Parallel | Vehicle Povidone-iodine 12-16 (unspecified); 14 average | n=30 | Mild | Itching Overall change/physician | ↓ Major losses to followup. Outcome assessor not blinded. | Betadine was an effective treatment for mild acne.
#236 Milikan, 1976 Columbia, USA Parallel | Tetracycline + vehicle Povidone-iodine + tetracycline 12-16 (unspecified) | n=30 | Mod/sev | Itching Overall change/physician | ↓ Major losses to followup. Outcome assessor not blinded. | Povidone-iodine skin cleanser may not penetrate deeply enough to produce significant improvement in moderate acne.
#237 Miller, 1986 London, UK Parallel | Cyproterone (2 mg) + ethinyl estradiol Cyproterone (.05 mg) + ethinyl estradiol Norethisterone + placebo + ethinyl estradiol 8, 16, 26 | n=90 female 90 male 0 Age 23.7 y | Mod/sev | Face severity (Leeds) Face severity/photo Macules (count) Nodules (count) Papules (count) Systemic reactions I > once Systemic reactions I once only Systemic reactions II > once Systemic reactions II once only Total severity (Leeds) | | Cyproterone and norethisterone were both effective. Cyproterone achieved effects faster. Side effects rates were comparable.
#238 Mills, 1978 Philadelphia, USA Parallel | Vehicle Tretinoin Erythromycin Erythromycin + tretinoin 2, 4, 6, 8 | n=80 female 35 male 45 Age 16.5 y | Mod/sev | Overall change/physician | ↓ Not randomized. Patient not blinded. Enroller not blinded. Major losses to followup. Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. | Erythromycin + tretinoin was more effective than either alone.
#239 Mills, 1979 Philadelphia, USA Parallel | Polystyrene Polyethylene Polyester Aluminum oxide Pumice 8 | n=50 | Mod/sev | Inflammatory change (%) Non-inflammatory change (%) Total lesion change (%) | ↓ Not randomized. Patient not blinded. Enroller not blinded. Major losses to followup. Outcome assessor not blinded. Arms not comparable. | The beneficial effects of these abradants were slight.
#241 Mills, 1986 Philadelphia, USA Parallel | Vehicle Benzoyl peroxide 2, 4, 6, 8 | n=50 | Mild/mod | Total lesions change (%) | ↑ No losses to followup. ↓ Not randomized. Inconsistent ascertainment across arms. Arms not comparable. | 2.5% benzoyl peroxide was more effective than vehicle and caused more side effects.
#242 Mills, 1986 Philadelphia, USA Parallel | Benzoyl peroxide (5%) Benzoyl peroxide (2.5%) 2, 4, 6, 8 | n=52 | Mild/mod | Total lesions change (%) | ↑ No losses to followup. ↓ Not randomized. Inconsistent ascertainment across arms. Arms not comparable. | There was no difference in efficacy or side effects between the 2.5% and 5.0% benzoyl peroxide.
#243 Mills, 1986 Philadelphia, USA Parallel | Benzoyl peroxide (10%) Benzoyl peroxide (2.5%) 2, 4, 6, 8 | n=50 | Mild/mod | Burning Erythema Peeling Total lesions change (%) | ↑ No losses to followup. ↓ Not randomized. Inconsistent ascertainment across arms. Arms not comparable. | 2.5% and 10% benzoyl peroxide showed equal efficacy. The 10% formulation caused more frequent and severe burning, erythema, and peeling.
#244 Mills, 1992 East Brunswick, USA Parallel | Erythromycin Clindamycin 2, 4, 8 | n=120 Age 18.0-30 y | Mild/mod | Comedones change (%) Dryness change (score) Erythema change (score) Inflammatory change (%) Papules change (%) Pustules change (%) Total lesions change (%) | ↑ No losses to followup. ↓ Enroller not blinded. Arms not comparable. | Erythromycin produced a greater reduction in pustules, papules, total inflamed lesions and total lesions, and was preferred by patients in terms of convenience, ease of application, and portability. Clindamycin was more effective for comedones.
#245 Monk, 1987 London, UK Parallel multicenter | Cyproterone + ethinyl estradiol Minocycline hydrochloride 8, 16, 24 | n=98 female 98 male 0 Age 23.4±5.1 y | Mild/mod | Comedones (count/max range) Comedones (count/median) GI+other side effects Gyn side effects Overall change/patient Papules (count/max) Papules (count/median) Papules range (count/max) Pustules (count/max) Pustules (count/median) Skin side effects | ↓ Patient not blinded. Enroller not blinded. Major losses to followup. Inconsistent ascertainment across arms. Outcome assessor not blinded. | Cyproterone-ethinyl estradiol and minocin were found to be equally effective in reduced the lesion count for comedones, papules and pustules and in pts subjective assessment of their skin.
#246 Morganti, 1997 Italy Parallel split face | Soybean liposome Glycolic acid + soybean liposome 4, 8, 12 | n=40 female 20 male 20 Age 16.0±3.0 y | Mild/mod | Closed comedones (count) Closed comedones change (%) Open comedones (count) Open comedones change (%) Papules (count) Papules change (%) Pustules (count) Pustules change (%) Withdrawals due to side effects | ↑ No losses to followup. | Glycolic acid and soybean liposome was more effective and acted more quickly than soybean liposome alone.
#247 Morginson, 1960 Salt Lake City, USA Parallel | Oleandomycin Triacetyl-oleandomycin 4-8 (unspecified) | n=142 | Can't say | Overall change/physician | ↓ Not randomized. Major losses to followup. Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. Execution not as designed. | Triacetyl-oleandomycin is effective.
#248 Moroni, 1976 Reggio Emilia, Italy Parallel | Quinestradol Placebo 8 | n=60 female 60 male 0 | Mild/mod | Comedones (count) Total lesions (count) | ↓ Not randomized. Major losses to followup. | Quinestradol is effective, especially for comedones.
#249 Muhlemann, 1986 London, UK Cross-over | Placebo Spironolactone 12 | n=58 female 58 male 0 | Mild/mod | Change (count) Overall change/patient Positive side effects Severity/photo Side effects Total lesions [phase i+phase ii] (count) | ↑ Data shows outcome assessor blinded. ↓ Major losses to followup. | Spironolactone significantly improved acne.
#250 Murphy, 1962 Unknown Cross-over | Placebo Oxytetracycline Unspecified | n=76 female 50 male 26 Age 11.0-33 y | Mod/sev | Severity change [phase i] Severity change [phase ii] Side effects | ↓ Not randomized. Inconsistent ascertainment across arms. Arms not comparable. | Oxytetracycline in low dosage over a prolonged period of time was safe and effective.
#253 Nordin, 1981 Vasteras, Sweden Parallel | Tretinoin Motretinide (bid) Motretinide (qd) 8 | n=60 female 39 male 21 Age 15.0 y | Mod/sev | Overall change/physician Papules (count) Pustules (count) | ↑ No losses to followup. | Motretinide was an effective alternative to tretinoin.
#255 Norris, 1991 Leeds, UK Parallel | Oxytetracycline (oral) + vehicle Benzoyl peroxide + placebo (oral) Tetracycline (topical) + placebo (oral) 8, 12 | n=69 female 45 male 24 Age 12.0-33 y | Mod | Back severity (Leeds) Chest severity (Leeds) Face severity (Leeds) Inflammatory (count) Non-inflammatory (count) Side effects | ↓ Inconsistent ascertainment across arms. | Topical tetracycline was as effective as either 5% benzoyl peroxide gel or oral tetracycline.
#257 Olafsson, 1989 Reykjavik, Iceland Parallel | Doxycycline + placebo Minocycline + placebo 4, 8, 12 | n=79 female 44 male 35 Age 20.5 y | Mod/sev | Closed comedones (count) Open comedones (count) Papules (count) Pustules (count) Total lesions (count) Withdrawal due to side effects | | Doxycyline and minocycline were equally effective.
#259 Orris, 1978 New York City, USA Parallel multicenter | Vehicle Zinc sulfate 4, 6, 8, 10, 12 | n=30 female 0 male 22 Age 19.1 y | Mild/mod | Closed comedones (count) Open comedones (count) Papules (count) Pustules (count) | ↓ Major losses to followup. | Oral zinc produced no benefit in males with moderate acne.
#260 Packman, 1996 Collegeville, USA Parallel multicenter | Erythromycin + benzoyl peroxide Clindamycin phosphate 2, 4, 7, 10 | n=205 female 205 male 0 Age 23.0-50 y | Mild/mod | Comedones (count) Inflammatory (count) Overall change (score) Side effects | ↑ Data show patient blinded. Data shows enroller blinded. No losses to followup. Data shows outcome assessor blinded. | Topical erythromycin with benzoyl peroxide was more effective than clindamycin.
#261 Padilla, 1981 Albuquerque, USA Parallel | Tetracycline hydrochloride Clindamycin 2, 4, 6, 8 | n=52 female 26 male 23 Age 22.3 y | Mild/mod | Erythema Itching/burn Overall improvement (discretized %) Peeling Side effects Total lesions (count) | ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. | Topical clindamycin was superior to topical tetracycline for treatment of mild-moderate acne. Both produced minimal side effects.
#263 Palatsi, 1984 Oulu, Finland Parallel multicenter | Levonorgestrel + ethinyl estradiol Desogestrel + ethinyl estradiol 24 | n=54 Age 24.0 y | Can't say | Severity change Side effects | ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. Arms not comparable. | Desogestrel + ethinyl estadiol was superior to levonorgestrel + ethinyl estadiol.
#264 Palatsi, 1986 Oulu, Finland Parallel | Levonorgestrel + ethinyl estradiol Desogestrel + ethinyl estradiol 24 | n=33 Age 24.0 y | Mild/mod | Severity (Allen-Smith) | ↑ No losses to followup. ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. | Desogestrel and ethinyl estadiol produced more improvement than levonorgestrel + ethinyl estadiol.
#265 Panzer, 1977 New Orleans, USA Parallel | Tetracycline Clindamycin 1, 2, 4, 8 | n=48 female 30 male 18 Age 17.5 y | Mod | Comedones (count) Esophagitis Mild diarrhea and cramping Overall change/physician Overall change/physician (rating) Pustules (count) Severity (Panzer) | ↑ Randomized. Referral population. ↓ Major losses to followup. Arms not comparable. | Clindamycin 1% and tetracycline showed similar efficacy.
#266 Paranjpe, 1995 Pune, India Parallel | Sunder vati Shankhabhasma vah Placebo Thiostanin Sookshama triphala 2, 4, 6 | n=82 female 40 male 42 Age 21.1 y | Mod | Inflammatory (count) Non-inflammatory (count) | ↑ Data shows outcome assessor blinded. | Sunder vati taken orally was effective in the treatment of acne vulgaris.
#267 Parker, 1987 Portland, USA Parallel | Clindamycin (solution) Clindamycin (gel) 3, 6, 9, 12 | n=60 | Mild | Open comedones (count) Overall change/investigator Overall change/patient Pustules (count) Side effects | ↓ Patient not blinded. Inconsistent ascertainment across arms. Arms not comparable. | Topical clindamycin phosphate gel and topical 1% clindamycin phosphate solution showed equal efficacy for treatment of moderately severe acne. [By the Combined Acne Severity Classification, these patients' acne is classified as “mild.”] Gel was less drying than solution.
#268 Peacock, 1990 Manchester, UK Parallel multicenter | Minocycline Clindamycin 2, 4, 8, 12 | n=80 female 28 male 52 Age 21.0 y | Mod/sev | Inflammatory (count) Non-inflammatory (count) Overall assessment (vas) Overall change/patient Side effects | ↑ Data shows enroller blinded. No losses to followup. Specific population. ↓ Patient not blinded. | Minocycline was twice as expensive as clindamycin. Both treatments were effective and there were no major differences in efficacy or side effects.
#269 Peck, 1982 Bethesda, USA Parallel | Isotretinoin Placebo 4, 8 | n=33 | Sev | Cysts change (%) Reduction in application due to side effects | ↑ Randomized. No losses to followup. | Isotretinoin was more efficacious than placebo for patients with treatment-resistant cystic acne.
#270 Pedace, 1971 San Diego, USA Parallel | Tretinoin Vehicle 4-12 (unspecified) | n=61 Age 17.0-21 y | Can't say | Comedones severity Improvement in papules Improvement on pustules Overall change Side effects | ↓ Enroller not blinded. Arms not comparable. | Tretinoin was superior to placebo.
#271 Pettit, 1959 Liverpool, UK Parallel | Serum gonadotrophin Placebo 12 | n=40 female 17 male 23 | Mild/mod/sev | Overall change/patient with physician | ↑ Data show patient blinded. Data shows enroller blinded. Data shows outcome assessor blinded. ↓ Major losses to followup. Inconsistent ascertainment across arms. Arms not comparable. | Treatment with serum gonadotrophin treatment did not improve acne.
#272 Plewig, 1969 Philadelphia, USA Parallel | Vitamin A Sulfur + resorcinol Benzoyl peroxide 14 | n=189 | Can't say | Total lesions change (%) | ↓ Not randomized. Patient not blinded. Enroller not blinded. Major losses to followup. Inconsistent ascertainment across arms. Outcome assessor not blinded. Arms not comparable. Execution not as designed. | Vitamin A was superior to both benzoyl peroxide and sulphur + resorcinol.
#273 Plewig, 1970 Philadelphia, USA Cross-over | Doxycycline Placebo 4, 8 | n=62 female 36 male 88 Age 19.0 y | Mild | Comedones (discretized %) Cysts Inflammatory (discretized %) Papules change Pustules Side effects Total inflammatory [phase i] (count) Total inflammatory [phase ii] (count) | ↓ Major losses to followup. | Doxycycline was an effective treatment for inflammatory acne but not for non-inflammatory acne.
#274 Pochi, 1988 Boston, USA Parallel multicenter | Vehicle Erythromycin 4, 8 | n=187 female 98 male 89 Age 20.8±6.4 y | Mild/mod | Closed comedones (count) Open comedones (count) Papules (count) Pustules (count) | ↑ Randomized. Specific population. ↓ Inconsistent ascertainment across arms. | Erythromycin 2% gel produced greater improvement than vehicle in facial acne.
#275 Poulos, 1976 St. Louis, USA Parallel | Tetracycline hydrochloride Clindamycin hydrochloride 8 | n=47 female 19 male 28 Age 13.0-34 y | Sev | Diarrhea Lesions change Overall change/patient (vas) | ↓ Not randomized. Enroller not blinded. Major losses to followup. Outcome assessor not blinded. Arms not comparable. | Clindamycin and tetracycline were equivalent.
#276 Prendiville, 1988 Middlesex, UK Parallel multicenter | Isotretinoin Dapsone 4, 8, 16, 20, 28, 36 | n=40 female 0 male 40 Age 16.0-31 y | Sev | Chest/back total lesions (count) Face/neck total lesions (count) Overall change/patient vas (p value) Overall change/patient vas (p-value) Post-therapy chest/back total lesions (count) Post-therapy face/neck total lesions (count) Post-therapy overall change/patient vas (p value) Post-therapy total severity/photo (Leeds) Side effects Total severity/photo (Leeds) | ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. | Isotretinoin was better than dapsone.
#277 Prince, 1981 Iowa City, USA Parallel matched split face | Erythromycin Vehicle 2, 4, 6, 8 | n=73 female 68 male 70 Age 20.3±2.2 y | Mild/mod | Inter-treatment lesion change Inter-treatment lesion change [female] Inter-treatment lesion change difference (count) Inter-treatment lesions change [male] Lesions change Lesions change [female] Lesions change [male] | ↓ Enroller not blinded. | Topical erythromycin solution showed greater reduction in lesion counts than placebo solution, but differences were not clinically significant.
#278 Prince, 1982 Iowa City, USA Parallel split face | Benzoyl peroxide + urea Benzoyl peroxide 2, 4, 6, 8 | n=39 female 64 male 14 Age 23.0±3.6 y | Mod | Inflammatory (count) Inflammatory change Total lesions (count) | | There was no added benefit associated with addition of urea to benzoyl peroxide in treating moderate acne.
#279 Rapaport, 1982 Los Angeles, USA Parallel | Tetracycline hydrochloride + placebo (topical) Erythromycin + placebo (oral) 2, 4, 8, 12 | n=54 female 32 male 22 Age 22.9±5.7 y | Mod/sev | Closed comedone change (count) Closed comedones change (count) Closed comedones severity change (vas) Comedones change (count) Inflammatory change (count) Open comedone change (count) Open comedones severity change (vas) Overall change/physician, patient Papules change (count) Papules severity change (vas) Pustules change (count) Pustules severity change Withdrawals due to side effects | ↑ Data show patient blinded. Data shows outcome assessor blinded. | Topical erythromycin was more effective and produced fewer side effects than oral tetracyline.
#280 Redmond, 1997 USA Parallel multicenter | Norgestimate + ethinyl estradiol Placebo 4, 8, 12, 16, 20, 24, 26 | n=250 female 231 male 0 Age 28.4 y | Mod | Adverse events Comedones change (count) Inflammatory change (count) Overall change/investigator Overall change/patient Total lesions change (count) | ↑ Randomized. Data show patient blinded. | Norgestimate + ethinyl estradiol was effective.
#283 Rietschel, 1983 Atlanta, USA Parallel | Tretinoin + clindamycin Tretinoin Clindamycin 2, 4, 6, 8 | n=64 Age 19.6 y | Mild/mod/sev | Comedones change (%) Dryness (severity) Erythema (severity) Overall change Papules change (%) Pustules change (%) Severity (Cook) | No losses to followup. ↓ Arms not comparable. | All were similar in efficacy and well tolerated.
#284 Riley, 1961 Charleston, USA Parallel | Placebo Hydrochlorthiazide 8 | n=50 female 28 male 22 Age 8.0-29 y | Can't say | Overall change | ↓ Not randomized. Patient not blinded. Enroller not blinded. Major losses to followup. Outcome assessor not blinded. Arms not comparable. | Hydrochlorothiazide was no more effective than placebo.
#285 Rivkin, 1980 Los Angeles, USA Parallel | Erythromycin Vehicle 2, 4, 8, 10, 12 | n=26 female 20 male 6 Age 24.9 y | Mod/sev | Overall change/physician Papules change (%) Pustules change (%) | Data show patient blinded. Data shows enroller blinded. No losses to followup. ↓ Outcome assessor not blinded. Arms not comparable. | Topical erythromycin is efficacious for moderately severe acne.
#287 Robinson, 1961 Baltimore, USA Parallel | Neomycin Vehicle Hydrocortisone Sulfur Resorcinol + neomycin + hydrocortisone F + sulfur Resorcinol 8-24 (unspecified) | n=79 Age 11.0-30 y | Can't say | Overall change/physician Side effects | ↓ Not randomized. Major losses to followup. Inconsistent ascertainment across arms. Arms not comparable. Execution not as designed. | Resorcinol, neomycin, and sulphur, did not differ from base (vehicle) in effectiveness.
#288 Robinson, 1961 Baltimore, USA Parallel | Vehicle Hydrocortisone + sulfur Neomycin + sulfur Neomycin + resorcinol + hydrocortisone + sulfur Resorcinol Hydrocortisone Neomycin Sulfur Unspecified | n=188 | Can't say | Overall change/physician Side effects | ↓ Not randomized. Major losses to followup. Inconsistent ascertainment across arms. Arms not comparable. Execution not as designed. | Sulphur, neomycin, and hydrocortisone did not differ in effectiveness.
#291 Robledo, 1988 Madrid, Spain Parallel multicenter | Tetracycline Clindamycin 2, 4, 6, 8 | n=92 Age 15.0-30 y | Mild | Open comedones change (count) Papules change (count) Pustules change (count) Pustules change (count) Severity assessment Side effects | ↑ No losses to followup. Referral population. ↓ Inconsistent ascertainment across arms. | Topical clindamycin was better at reducing pustules than topical tetracycline. There was no significant difference in reduction of comedones or papules.
#293 Ross, 1961 Pretoria, South Africa Parallel | Placebo Dapsone Unspecified | n=46 female 25 male 19 | Mild/mod/sev | Severity change Severity change [female] Severity change [male] Side effects Side effects [female] Side effects [male] | ↑ No losses to followup. ↓ Not randomized. | A statistically significant number of cases responded favorably to dapsone.
#294 Roth, 1964 Daly City, USA Parallel matched | Salicylic acid Placebo 1, 2, 3, 4, 5, 9-10 | n=30 female 11 male 19 Age 13.0-32 y | Mild/mod | Acne change Acne change (% face) Face oiliness change (% face) Local reactions Oiliness change | ↓ Not randomized. Patient not blinded. Enroller not blinded. Major losses to blinded. Major losses to followup. Outcome assessor not blinded. Execution not as designed. | Salicylic acid reduced oiliness and improved acne.
#295 Rushton, 1962 Sheffield, UK Parallel split face | Vehicle Epiestriol 12 | n=50 | Can't say | Inter-treatment severity change Overall change/physician | ↑ Referral population. | Epiestriol did not produce any significant effect.
#297 Saihan, 1981 Bristol, UK Parallel | Vehicle Chloramphenicol + hydrocortisone 4, 8 | n=32 female 22 male 10 | Mild/mod | Overall change/patient Overall change/physician Severity (Burton) Withdrawals due to side effects | ↓ Arms not comparable. | Chloranpheniol + hydrocortisone was more effective.
#298 Samuelson, 1985 East Stroudsburg, USA Parallel | Minocycline Tetracycline 6, 12 | n=62 female 40 male 22 Age 19.0 y | Mod/sev | GI symptoms Severity/investigator (Samuelson) Severity/patient (Samuelson) Vaginal infection | ↑ Data shows enroller blinded. Data shows outcome assessor blinded. | Minocycline was better than tetracycline using photographic assessment.
#299 Savin, 1966 New Haven, USA Parallel | Placebo Tetracycline + sodium novobiocin 4 | n=42 female 24 male 18 Age 15.0-25 y | Mod/sev | Overall change/physician Side effects | ↑ Data show patient blinded. Data shows enroller blinded. No losses to followup. Data shows outcome assessor blinded. ↓ Arms not comparable. | Tetracycline + sodium novobiocin was more effective than placebo.
#300 Schachner, 1990 Miami, USA Parallel | Clindamycin phosphate Erythromycin + zinc 3, 6, 9, 12 | n=103 female 40 male 52 Age 19.1 y | Mod | Comedones change (%) Cutaneous Severity change (Cook %) Total inflammatory change (%) | ↓ Patient not blinded. Enroller not blinded. | Erythromycin plus zinc provided better therapeutic benefits, in a shorter time, than topical clindamycin. Both medications were equally tolerated.
#301 Schachner, 1990 Miami, USA Parallel | Vehicle Erythromycin + zinc 2, 6, 10, 12, 16, 20, 24, 28, 32, 36, 40, 44, 48, 52 | n=73 female 73 male 0 Age 13.0-36 y | Mod | Comedones (count) Inflammatory (count) Severity (Cook) Severity change (Cook) Side effects | ↓ Major losses to followup. Arms not comparable. | Erythromycin + zinc was more effective than vehicle after 6 weeks treatment.
#302 Schafer Korting, 1994 Berlin, Germany Parallel split face multicenter | Tretinoin combined Tretinoin (0.01%) Tretinoin (0.05%) Tretinoin (0.025%) 2, 4, 6, 12 | n=20 female 14 male 6 Age 24.0 y | Mild | Acne flare-up Burning Comedones (count) Comedones (improvement) Erythema Inflammatory (count) Inflammatory (improvement) Scaling | ↓ Execution not as designed. | Liposomal tretinoin (combined) provided comparable efficacy to tretinoin 0.025% and tretinoin 0.05%, and performed slightly better for comedones. It was also better tolerated.
#303 Shalita, 1984 Brooklyn, USA Parallel multicenter | Clindamycin Erythromycin 2, 4, 8, 12 | n=178 female 116 male 50 Age 22.6 y | Mod | Inflammatory (count) Inter-treatment preference/patient Non-inflammatory (count) Side effects | | Erythromycin and clidamycin showed comparable effectiveness but erythromycin produced somewhat more side effects.
#304 Shalita, 1989 Brooklyn, USA Cross-over | Salicylic acid Benzoyl peroxide 2, 4 | n=30 female 15 male 15 Age 13.0-31 y | Mild | Comedones change [phase i] (%) Comedones change [phase ii] (%) | ↑ No losses to followup. ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. | Salicylic acid was effective in treatment of comedonal acne; benzoyl peroxide was not.
#305 Shalita, 1995 Brooklyn, USA Parallel multicenter | Nicotinamide Clindamycin 4, 8 | n=76 female 53 male 23 Age 21.3 y | Mod | Inflammatory change (%) Local side effects Overall change/physician Severity (Allen-Smith) Severity change (Allen-Smith %) | ↓ Major losses to followup. Outcome assessor not blinded. Arms not blinded. Arms not comparable. | 4% nicotinamide and 1% clindamycin gel were equivalent in efficacy.
#306 Shalita, 1996 Brooklyn, USA Parallel multicenter | Adapalene Tretinoin 2, 4, 8, 12 | n=288 Age 12.0-30 y | Mod | % Burning grade I % Dryness grade I % Erythema grade I % Scaling grade Inflammatory change (%) Non-inflammatory change (%) Severity change Total lesions change (%) | ↑ Randomized. General population. ↓ Outcome assessor not blinded. Arms not comparable. | Adapalene 0.1% gel bid was more effective than tretinoin 0.025% gel.
#307 Sheehan-Dare, 1990 Leeds, UK Parallel matched | Clindamycin phosphate + placebo Minocycline + placebo 4, 8, 12 | n=64 female 24 male 42 Age 14.0-35 y | Mod/sev | Diarrhea Facial erythema Facial stinging Inflammatory (count) Non-inflammatory (count) Severity (Leeds) | ↑ No losses to followup. Referral population. | Both topical clindamycin and oral minocycline were effective in the treatment of moderate-severe acne.
#310 Sklar, 1996 Dallas, USA Parallel | Placebo Benzoyl peroxide + glycolic acid + zinc sulfur Benzoyl peroxide + erythromycin 1, 2, 4, 8, 12 | n=92 Age 16.0-30 y | Mild/mod | Comedones (count) Inflammatory (count) Side effects Total lesions (count) | ↑ Data show patient blinded. Data shows enroller blinded. No benzoyl peroxide as a combo losses to followup. | Triaz 10% as a special gel seems to optimize therapeutic power of drug rather than by itself.
#311 Smit, 1978 Wageningen, The Netherlands Parallel | Minocycline Doxycycline 12 | n=18 | Mild/mod | Severity change (Smit) Side effects | ↓ Arms not comparable. | Doxycycline and minocycline were equally effective for severe acne. [By the Combined Acne Severity Classification, these patients' acne is classified as “mild.”]
#312 Smith, 1962 London, UK Parallel | Placebo Demethylchlortetracycline Phenethicillin 4 | n=66 female 22 male 38 | Mild/mod/sev | Overall change/patient (score) Overall change/physician Severity change/photo (score) | ↑ Referral population. ↓ Patient not blinded. | There were no significant differences, between the treatments, including placebo.
#313 Smith, 1976 Augusta, USA Parallel | Tetracycline hydrochloride (oral) + placebo Tetracycline hydrochloride (topical) + placebo Placebo + placebo 2, 4, 7, 10, 12 | n=149 female 80 male 55 Age 19.9 y | Mild/mod | Severity (Cook) | ↑ Local population. | Topical tetracycline plus oral tetracycline and oral tetracycline were both more effective than placebo.
#314 Smith, 1980 Albequerque, USA Parallel | Vehicle Benzoyl peroxide (20%) 8 | n=59 female 35 male 16 Age 23.0 y | Mod | Allergic dermatitis Redness/peeling Total lesion (count) Total lesions change (descretized %) | Local population. | Benzoyl peroxide 20% was significantly more effective in reducing inflammatory acne.
#315 Sommer, 1997 Leeds, UK Parallel | Placebo Fusidin 1, 4, 9, 12 | n=56 female 15 male 41 Age 18.8±1.1 y | Can't say | Inflammatory change (%) Non-inflammatory change (%) Severity change (Leeds) | | Fusidin was no better than placebo.
#316 Spellman, 1998 San Diego, USA Parallel multicenter | Azelaic acid + glycolic acid Tretinoin + vehicle 4, 8, 12 | n=70 female 53 male 17 Age 24.5 y | Mild | Dryness (severity) Erythema (severity) Inflammatory change (%) Non-inflammatory change (%) Papules change (%) Scaling (severity) Side effects (patient assessment) | | Azelaic acid + glycolic acid led to a greater reduction in papules and inflammatory lesions, and caused less dryness, scaling and erythema than tretinoin.
#317 Stankler, 1976 Aberdeen, UK Parallel | Tetracycline Tetracycline + proteolytic enzymes 12 | n=51 female 19 male 32 | Sev | Severity change | ↑ Data show patient blinded. Data shows enroller blinded. Data shows outcome assessor blinded. ↓ Arms not comparable. | The combination of tetracycline and enzyme was better than tetracycline alone, but not at a statistically significant level.
#318 Stoughton, 1980 San Diego, USA Parallel | Clindamycin (lotion) + Placebo (oral) Tetracycline (oral) + Placebo (lotion) 2, 3, 4, 6, 8 | n=50 Age 18.0-30 y | Mod | Overall change/patient (Stoughton) Papules (count) Side effects | No losses to followup. Referral population. ↓ Not randomized. Outcome assessor not blinded. | Clindamycin phosphate 1% is at least equal to tetracycline 500mg/d.
#320 Strauss, 1984 Iowa City, USA Parallel multicenter | Isotretinoin (1.0) Isotretinoin (0.1) Isotretinoin (0.5) 4, 8, 12, 16, 20; 4, 8, 12 post-therapy; 60-90 post-therapy or 4, 8, 12, 16, 20;24, 28, 32, 80-110. | n=150 female 14 male 109 Age 22.9 y | Sev | Inflammatory change post therapy/face (%) Inflammatory change/face (%) Inflammatory change/trunk (%) Inflammatory change/trunk post-therapy (%) Local side effects Overall assessment/patient 1 yr. later Skin side effects Systemic side effects | Randomized. Data shows outcome assessor blinded. Specific population. | The maintenance of the clinical improvement was much greater when higher dosages were used. There was no sufficiently consistent pattern of side effects differences.
#321 Strauss, 1984 Iowa City, USA Parallel | Zinc + erythromycin Vehicle 4, 8, 10 | n=22 Age 13.0-35 y | Mild/mod | Inflammatory change (%) | Randomized. No losses to followup. ↓ Inconsistent ascertainment across arms. Arms not comparable. | Topical erythromycin 4% with zinc decreases inflammatory lesion counts.
#323 Swinyer, 1980 Salt Lake City, USA Parallel | Tretinoin + benzoyl peroxide + water avoidance Tretinoin + emollient + tetracycline Tetracycline + sulfur/salicylic acid + polyethylene 4, 8, 12, 16 | n=122 female 78 male 44 Age 18.2±2.3 y | Mild/mod/sev | Comedones change (%) Dryness Erythema Inflammatory change (%) Oiliness Papules+pustules change (%) Peeling Total lesions change (%) | ↑ Randomized. Data shows enroller blinded. No losses to followup. Data shows outcome assessor blinded. Referral population. ↓ Patient not blinded. | A topical program of tretinoin, benzoyl peroxide, and water avoidance was as effective as tetracycline and tretinoin and better than tetracycline with abrasive cleansers.
#324 Swinyer, 1988 Salt Lake City, USA Parallel | Clindamycin phosphate Benzoyl peroxide 2, 4, 8, 12 | n=60 female 34 male 26 Age 19.8 y | Mod | Inflammatory change (%) Local reactions/Dryness Local reactions/Erythema Local reactions/Oiliness Local reactions/Peeling Non-inflammatory change (%) Total lesions change (%) | ↑ No losses to followup. ↓ Patient not blinded. | Benzoyl peroxide gel was superior to clindamycin phosphate.
#325 Thappa, 1994 Bajaj Nagar, India Parallel | Gugulipid Tetracycline 12 | n=20 female 5 male 15 Age 16.0-25 y | Sev | Inflammatory change (%) Non-inflammatory change (%) Post-therapy relapse Severity change (Michaelsson) | ↑ No losses to followup. ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. Arms not comparable. | There was no statistical difference between tetracycline and gugulipid. Patients with oily skin responded better to gugulipid suggesting use of gugulipid in nodulocystic acne.
#326 Thomas, 1982 Gavelson, USA Parallel multicenter | Erythromycin Clindamycin 2, 4, 8, 12 | n=72 Age 12.0-55 y | Mod/sev | Closed comedones (count) Nodes+cysts (count) Non-inflammatory (count) Open comedones (count) Overall change/patient Total inflammatory (count) Total lesions (count) | | Patients responded equally to erythromycin and clindamycin.
#327 Thomsen, 1980 Iowa City, USA Parallel | Clindamycin hydrochloride Vehicle 2, 4, 6, 8 | n=18 female 11 male 3 Age 22.3 y | Mild/mod | Diarrhea Erythema Itching Nodules (count) Papules (count) Peeling Pustules (count) Severity/patient | ↓ Not randomized. | 3 of 9 clindamycin patients showed clinical improvement.
#328 Tong, 1994 New South Wales/Canperdown, Australia Parallel | Metronidazole Placebo 4, 8, 12 | n=96 female 47 male 49 Age 20.7±4.6 y | Mild/mod | Inflammatory (count) Local irritation Non-inflammatory (count) Side effects | ↑ No losses to followup. Data shows outcome assessor blinded. | There was no significant benefit to using 0.75% metronidazole gel over placebo in reducing counts of inflamed and non-inflamed lesions.
#329 Tucker, 1984 Houston, USA Parallel | Clindamycin Benzoyl peroxide Clindamycin + benzoyl peroxide 2, 4, 6, 8, 10 | n=79 female 45 male 34 Age 12.0-30 y | Mod | Comedones (count) Cysts (count) Irritancy (score) Papules (count) Pustules (count) Severity change (Michaelsson %) | ↓ Not randomized. Patient not blinded. Enroller not blinded. Major losses to followup. Outcome assessor not blinded. Arms not comparable. | Combination therapy consistently demonstrated the best overall efficacy as regards severity.
#332 van der Meeren, 1983 Amsterdam, The Netherlands Parallel multicenter | Isotretinoin (1.0) Isotretinoin (0.5) 4, 8, 12 | n=58 female 0 male 58 Age 22.0±6.0 y | Mild/mod/sev | Comedones (median) Infiltrates (median) Local reaction Papules (median) Pustules (median) Side effects (number) Withdrawals | Referral population. ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. | Isotretinoin 0.5 mg/kg is preferred to 1.0 mg/kg for conglobate acne.
#335 Van Neste, 1986 Brussels, Belgium Parallel matched split face | Benzoyl peroxide + isoconazole nitrate Benzoyl peroxide + miconazole nitrate 2, 4, 8 | n=20 female 26 male 6 Age 13.0-28 y | Mild/mod | Closed comedones change (count) Erythema Mild itching Open comedones change (count) Open comedones change (count) Papules change (count) Pustules change (count) Transient scaling | ↑ Randomized. Data show patient blinded. Data shows enroller blinded. Data shows outcome assessor blinded. | There was no difference between benzoyl peroxide + isoconazole nitrate and benzoyl peroxide + miconazole nitrate.
#336 Verma, 1980 Rohtah, India Parallel | Zinc sulfate Vehicle 6 | n=56 female 21 male 35 | Mod | Cysts (count) Infiltrates (count) Oiliness Papules (count) Pustules (count) Severity change Side effects | ↑ No losses to followup. Data shows outcome assessor blinded. ↓ Not randomized. Inconsistent ascertainment across arms. | Zinc was better than placebo.
#338 Verschoore, 1991 Warsaw, Poland Parallel | Adapalene (0.1%) Tretinoin Adapalene (0.03%) 8, 12 | n=72 | Mild/mod/sev | Inflammatory change (%) Non-inflammatory (count) Severe erythema Severity (Leeds) | ↑ Data shows enroller blinded. No losses to followup. ↓ Outcome assessor not blinded. Arms not comparable. | 0.1% adapalene may be an effective and safe treatment for mild to moderate acne.
#340 Wansker, 1961 Charlotte, USA Parallel | Placebo Tetracycline-novobiocin Triacetyl-oleandomycin Tetracycline-citric acid Tetracycline phosphate Erythromycin proprionate Erythromycin stearate 24-72 (unspecified) | n=91 Age 12.0-36 y | Mod/sev | Inter-treatment severity comparison | ↑ Data show patient blinded. Data shows enroller blinded. Data shows outcome assessor blinded. ↓ Major losses to followup. Inconsistent ascertainment across arms. Arms not comparable. | All of the antibiotics were more effective than placebo.
#341 Weimar, 1978 Iowa city, USA Parallel | Placebo Zinc sulfate 2, 4, 6, 8, 12 | n=52 female 28 male 24 Age 19.7 y | Mild/mod | Comedones (count) Cysts (count) GI distress Papules (count) Pustules (count) Severity (Michaelsson) | ↑ Randomized. Local population. ↓ Major losses to followup. Arms not comparable. | Zinc had a beneficial effect on pustules, but significant side effects were observed.
#342 Weismann, 1977 Copenhagen, Denmark Parallel | Vehicle Zinc sulfate 4, 8, 12 | n=39 female 9 male 30 Age 17.0-37 y | Mod | Infiltrates (count) Papules (count) Pustules (count) Side effects | ↑ Randomized. ↓ Major losses to followup. | Oral zinc sulphate did not affect acne.
#344 Wethered, 1964 UK Parallel multicenter | Fusidin (oral) Fusidin (topical) 2 | n=70 female 29 male 41 | Mild/mod/sev | Overall change/physician Severity change/photo Side effects | ↑ Data shows outcome assessor blinded. ↓ Not randomized. Patient not blinded. Enroller not blinded. Major losses to followup. Arms not comparable. | Fusidin orally or in ointment was not effective.
#346 Wexler, 1968 New York, USA Parallel | Vehicle Neomycin + methylprednisolone + sulfur + aluminum 4 | n=48 | Mild/mod/sev | Overall change/physician Patient satisfaction | Randomized. Data shows enroller blinded. No losses to followup. Data shows outcome assessor blinded. Referral population. ↓ Arms not comparable. | A polyvalent approach produces the best results.
#347 Wexler, 1968 New York, USA Parallel | Sulfur + aluminum chlorhydroxide Neomycin + methylprednisolone + sulfur + aluminum c 4 | n=48 | Mild/mod/sev | Overall change/physician Patient satisfaction | Randomized. Data shows enroller blinded. No losses to followup. Data shows outcome assessor blinded. Referral population. ↓ Arms not comparable. | A polyvalent approach produces the best results.
#349 Wong, 1984 Ann Arbor, USA Parallel | Ibuprofen + placebo Ibuprofen + tetracycline Tetracycline + placebo Placebo 4, 8 | n=68 female 12 male 48 Age 20.5 y | Mild/mod | Improvement Side effects overall Side effects specific Total change (%) Total lesion (count) | Randomized. Data show patient blinded. ↓ Outcome assessor not blinded. | The combination of ibuprofen tetracyline is effective when administered for 2 months.
#350 Wright, 1964 San Francisco, USA Parallel matched split face | Sham rays + hexachlorophene Grenz rays Grenz ray + hexachlorophene Untreated 24 | n=95 | Sev | Overall change/patient [acne conglobata] Overall change/patient [acne vulgaris] Pigmentation Severity change/patient-treated side [acne vulgaris] | ↑ No losses to followup. ↓ Enroller not blinded. Outcome assessor not blinded. | Grenz rays were not effective in treatment of acne.
#351 Yong, 1979 Singapore Parallel | Benzoyl peroxide (5%) Benzoyl peroxide (2.5%) 4-18 (end of therapy) | n=200 female 140 male 60 | Mild/mod/sev | Desquamation Eczematous reaction Erythema Hair discoloration Itching or burning Overall change/physician Pigmentation Pustular Side Effects | No losses to followup. Local population. ↓ Patient not blinded. Enroller not blinded. Outcome assessor not blinded. Arms not comparable. | No significant difference was found either in efficacy or severity of side effects.

Evidence Table A1. Articles/arms for class CLEANSER (TOPICAL)

Comp-Trial | | TARGET | | HEADING | | COMPARATOR | | Outcome Table(s)
Comp-Trial | | Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment | Outcome Table(s)
A.01.01 | 197 | Acidic syndet bar | No dose information. | | Bar soap | No dose information. | Composition of this soa | Continuous Discrete
A.01.015 | 239 | Aluminum Oxide | No dose information. | | Pumice | No dose information. | | Continuous (M)
A.01.04 | 235 | Povidone-iodine | No dose information. | | Vehicle | No dose information. | Up to tid. | Discrete
A.01.05 | 204 | Silicic acid | No dose information. | | Vehicle | No dose information. | | Continuous

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table A2. CONTINUOUS outcomes for class CLEANSER (TOPICAL)

Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Target | | Comparator | | Between P-value
Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Data Type: Mean (SD) | Within P | Data Type: Mean (SD) | Within P | Between P-value
197 ↑ Parallel | N=114 Mild | A.01.01 | Inflammatory (count) Baseline counts: 13 (Target)/15 | | Acidic syndet bar Percent Change*: −22 | .0001 | Soap Percent Change*: 05 | .0001 | NS*
| | | Non-inflammatory (count) Baseline counts: 7 (Target)/7 (Comparator) | Mid (12) | Percent Change*: −12 | | Percent Change*: 31 | | NS*
204 ↑ Parallel | N=30 Mod | A.01.05 | Comedones (count) Count location: Left cheek. | Short (6) | Silicic acid Raw count: 15 (66.) | .01 | Vehicle Raw count: 46 | NS | NS
| | | Cysts (count) Count location: Left cheek. Baseline counts: 1 (Target)/0 (Comparator) | Short (6) | Percent Change*: −100 | | Percent Change*: −25 | NS
| | | Papules (count) Count location: Left cheek. Baseline counts: 11 (Target)/11 (Comparator) | Short (6) | Percent Change*: −91 | .001 | Percent Change*: 00 | NS | NS
| | | Pustules (count) Count location: Left cheek. Baseline counts: 7 (Target)/6 (Comparator) | Short (6) | Percent Change*: −100 | .0001 | Percent Change*: −06 | .01 | NS

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., - our assessment of entry severity of study patients. “P”- parallel study, “S”- split face design. TARGET and COMPARATOR: “Percent change”- an outcome derived from individual final and baseline measures; “Percent change*”- we calculated a group-based percentage change; “Change” - raw difference from baseline; “Change*” - calculated change; “Measure” - an outcome measure with no baseline comparison. SD: standard deviation. WITHIN P: P-value with respect to baseline in one arm. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table A3: DISCRETE outcomes for class CLEANSER (TOPICAL)

Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Treatment | Comparator | Between P-value
Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Attribute: Number of patient | Attribute: Number of patients | Between P-value
197 ↑ Parallel Mild N=114 | A.01.01 | Itching | Mid (12) | Acidic syndet bar Present 0 Absent 57 | Soap Present 12 Absent 45
| | Redness | Mid (12) | Present 1 Absent 56 | Present 15 Absent 41
| | Scaling | Mid (12) | Present 1 Absent 56 | Present 12 Absent 45
235 ↓ Parallel Mild N=30 | A.01.04 | Itching | Long (14) | Povidone-iodine Itching 0 | Vehicle Itching 1
| | Overall change/physician | Long (14) | Much improved or improved 9 No change or worse 1 | Much improved or improved 3 No change or worse 4

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., - our assessment of entry severity of study patients. “P”- to parallel study, “S”- split face design. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table B1. Articles/arms for class KERATOLYTIC (TOPICAL)

Comp-Trial | | TARGET | | HEADING | | COMPARATOR | | Outcome Table(s)
Comp-Trial | | Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment | Outcome Table(s)
B.01.01 | 77 | Azelaic acid | 20 % topical bid. | Dermo^®^ mild wash cleanser. | Placebo | No dose information. | Dermo^®^ mild wash clea | Continuous Discrete
| 187 | Azelaic acid | 20 % topical bid. | Washout period of 2-4 weeks. | Vehicle | No dose information | Washout period of 2-4 w | Continuous Discrete
B.01.02 | 52 | Azelaic acid | 20 % topical (qd 2 weeks, then bid) | | Benzoyl peroxide | 5 % topical (qd for 2 weeks then bid) | | Continuous
B.03.01 | 95 | Salicylic acid | 2 % topical bid. | | Vehicle | No dose information | | Continuous
| 294 | Salicylic acid | 1.5 % topical tid. | Tetracycline, uv light, vit A shampoos, hexachlorophene as needed. | Placebo | No dose information | Tetracycline or cyst vit | Continuous Discrete
B.05.01 | 86 | Quaterary ammonia complex of polythionates Polythionate | 1.5 % topical () 1.5 % topical bid. | | Polythionate | 2 % topical bid. | Element sulfur 1.2%; fre | Discrete
B.05.02 | 101 | Sulphurated lime | No dose information. | Apply heavy layer to face, leave on for 20 minutes then wash off with warm water. Shepard^®^'s soap. | Vehicle | No dose information | Apply heavy layer to fac | Continuous Discrete
B.06.01 | 191 | Resorcinol Salicylic acid Sulphur | No dose information. No dose information. No dose information. | Patients were allowed to continue other treatments. | Placebo | No dose information | Contents unstated. | Discrete
B.06.02 | 191 | Resorcinol Salicylic acid Sulphur | No dose information. No dose information. No dose information. | Patients were allowed to continue other treatments. | Resorcinol Salicylic acid Sulphur | No dose information No dose information No dose information | It is not stated explicitly | Discrete
B.07.01 | 165 | Aluminum chloride | 6.25 % topical (can't say) | | Vehicle | No dose information | | Discrete
B.07.02 | 228 | Sulphur Aluminum chlorhydroxide | 50 % topical bid. 100 % topical bid. | Modified placebo. | Vehicle | No dose information | | Discrete
B.07.04 | 176 | Gluconolactone | 14 % topical (can't say) | | Vehicle | No dose information | Vehicle of gluconolacto | Continuous Discrete
B.07.06 | 246 | Soybean liposome Glycolic acid | No dose information. No dose information. | Single preparation. | Soybean liposome | No dose information | Mavigen^®^ cleansing cr | Continuous Discrete

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table B2. CONTINUOUS outcomes for class KERATOLYTIC (TOPICAL)

Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Target | | Comparator | | Between P-value
Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Data Type: Mean (SD) | Within P | Data Type: Mean (SD) | Within P | Between P-value
77 ↑ Parallel | N=40 | B.01.01 | Inflammatory change (%) | Mid (12) | Azelaic acid Percent change: −50 | | Placebo Percent change: −10 | | 0.001
| | | Non-inflammatory change (%) | Mid (12) | Percent change: −50 | | Percent change: −25 | | 0.027
187 ↑ Parallel | N=92 Mod | B.01.01 | Comedones change (%) | Mid (12) | Azelaic acid Percent change: −56 | | Vehicle Percent change: 0 | | 0.05
| | | Inflammatory (count/median) | Mid (12) | Measure: 7 | | Measure: 16 | | 0.05
52 Parallel | N=309 Mild | B.01.02 | Inflammatory (count/median) | Short (4) | Azelaic acid Measure: 11 | sig | Benzoyl peroxide Measure: 9 | sig
| | | Overall change/physician (%) | Short (4) | Percent change: 28 | | Percent change: 32
| | | Inflammatory (count) Baseline counts: 19 (Target)/18 | | Percent Change*: −63 | | Percent Change*: −78
| | | Overall change/physician (%) | | Percent change: 47 | | Percent change: 50
| | | Good/excellent response (%) | | Percent change: 70 | | Percent change: 74
| | | Inflammatory (count/median)
↓ Parallel | N=30 Mild/mod | | Acne change (% face)
| | | Face oiliness change (% face)
| | | Acne change (% face)
| | | Face oiliness change (% face)
Parallel | Mild/mod | | Inflammatory (count) Baseline counts: 32 (Target)/32 | | Percent Change*: −09 | | Percent Change*: −03
95 Parallel | Mild/mod | | Non-inflammatory (count) Baseline counts: 50 (Target)/50 | | Percent Change*: −28 | | Percent Change*: −18
| | | Overall change/patient (scale)
| | | Total lesions (count) Baseline counts: 83 (Target)/83 | | Percent Change*: −18 | | Percent Change*: −10
| | | Inflammatory (count) Baseline counts: 32 (Target)/32 | | Percent Change*: −28 | | Percent Change*: −09
| | | Non-inflammatory (count) Baseline counts: 50 (Target)/50 | | Percent Change*: −46 | | Percent Change*: −26
| | | Overall change/patient (scale)
| | | Total lesions (count) Baseline counts: 83 (Target)/83 | | Percent Change*: −40 | | Percent Change*: −16
| | | Count location: Face.
| | | Comedones (count) Count location: Face. Baseline counts: 50 (Target)/50 (Comparator) | Short (4) | Percent Change*: −30 | NS | Percent Change*: −26 | NS
| | | Erythema Count location: Face. | Short (4) | Measure: 2 | NS | Measure: 3 | NS | NS
| | | Papules (count) Count location: Face. Baseline counts: 29 (Target)/41 (Comparator) | Short (4) | Percent Change*: −31 | .01 | Percent Change*: −38 | .01 | NS
101 Parallel | N=59 Mod | | Peeling Count location: Face. | Short (4) | Measure: 1 | NS | Measure: 1 | NS | NS
| | | Pustules (count) Count location: Face. Baseline counts: 13 (Target)/13 (Comparator) | Short (4) | Percent Change*: −62 | .03 | Percent Change*: −40 | .03 | NS
| | | Comedones (count) Count location: Face. Baseline counts: 50 (Target)/50 (Comparator) | Mid (10) | Percent Change*: −30 | .01 | Percent Change*: −24 | NS
| | | Erythema Count location: Face. | Mid (10) | Measure: 2 | NS | Measure: 3 | NS | NS
| | | Papules (count) Count location: Face. Baseline counts: 29 (Target)/41 (Comparator) | Mid (10) | Percent Change*: 75 | .01 | Percent Change*: −44 | .01 | 0.05
| | | Peeling Count location: Face. | Mid (10) | Measure: 1 | NS | Measure: 1 | NS | NS
| | | Pustules (count) Count location: Face. Baseline counts: 13 (Target)/13 (Comparator) | Mid (10) | Percent Change*: −57 | .03 | Percent Change*: −40 | .03 | NS
176 ↓ Parallel | N=150 Mod/sev | B.07.04 | Inflammatory change (%) Count location: Face. | Short (4) | Gluconolactone Percent change: −49 | | Vehicle Percent change: −39 | | NS
| | | Non-inflammatory change (%) | Short (4) | Percent change: −8 | | Percent change: −4 | | NS
| | | Total lesions change (%) | Short (4) | Percent change: −15 | | Percent change: −7
| | | Inflammatory change (%) | Mid (12) | Percent change: −59 | .001 | Percent change: −10 | NS | 0.05
| | | Non-inflammatory change (%) | Mid (12) | Percent change: −17 | NS | Percent change: −4 | NS
| | | Total lesions change (%) | Mid (12) | Percent change: −22 | .05 | Percent change: −5 | NS | NS
↑ Parallel | N=40 split face | | Closed comedones (count) | | Glycolic acid + soybean liposome
| | | Open comedones (count)
246 ↑ N=40 Parallel split face Mild/mod | | | Papules (count) | Short (4) | Raw count: 20 | .005 | Raw count: 29 | .005 | 0.01
| | | Closed comedones change (%) | Mid (12) | Percent change: −53 | | Percent change: −39 | | 0.01
| | | Open comedones change (%) | Mid (12) | Percent change: −65 | | Percent change: −50 | | 0.01
| | | Papules change (%) | Mid (12) | Percent change: −67 | | Percent change: −51
| | | Pustules change (%) | Mid (12) | Percent change: −86 | | Percent change: −57 | | 0.01

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., - our assessment of entry severity of study patients. “P”- parallel study, “S”- split face design. TARGET and COMPARATOR: “Percent change”- an outcome derived from individual final and baseline measures; “Percent change*”- we calculated a group-based percentage change; “Change” - raw difference from baseline; “Change*” - calculated change; “Measure” - an outcome measure with no baseline comparison. SD: standard deviation. WITHIN P: P-value with respect to baseline in one arm. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table B3: DISCRETE outcomes for class KERATOLYTIC (TOPICAL)

Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Treatment | Comparator | Between P-value
Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Attribute: Number of patient | Attribute: Number of patients | Between P-value
77 ↑ Parallel N=40 | B.01.01 | Local side effects | | Azelaic acid Present 2 Absent 18 | Placebo Present 1 Absent 19
187 ↑ Parallel Mod N=92 | B.01.01 | Burning | Mid (12) | Azelaic acid Present 4 Absent 39 | Vehicle Present 1 Absent 48
| | Erythema | Mid (12) | Present 2 Absent 41 | Present 1 Absent 48
| | Itching | Mid (12) | Present 2 Absent 41 | Present 0 Absent 49
| | Overall change/physician | Mid (12) | Excellent or good 28 Other 15 | Excellent or good 18 Other 31 | 0.05
| | Scaling | Mid (12) | Present 1 Absent 42 | Present 2 Absent 47
294 ↓ Parallel Mild/mod N=30 | B.03.01 | Acne change | Short (5) | Salicylic acid Greater than match 10 Equal 8 Worse than match 0 | Placebo Greater than match 0 Equal 8 Worse than match 10
| | Oiliness change | Short (5) | Greater than match 11 Equal 7 Worse than match 0 | Greater than match 0 Equal 7 Worse than match 11
| | Local reactions | Mid (9.5) | Skin burning 10 Eyes burning 1 | Skin burning 0 Eyes burning 0
| | Oiliness change | Mid (9.5) | Greater with match 5 Equal 6 Worse than match 6 | Greater with match 0 Equal 6
| | Acne change | Mid (12) | Greater than match 7 Equal 4 Worse than match 0 | Greater than match 0 Equal 4 Worse than match 7
101 Parallel Mod N=59 | B.05.02 | Severity change | Mid (10) | Sulfurated lime Excellent 9 Moderate 10 Slight 1 No change 6 | Vehicle Excellent 2 Moderate 5 Slight 2 No change 4 | 0.015
| | | | Worse 4 Dropouts 0 | Worse 9 Dropouts 7
191 ↑ Parallel split face Mild/mod/sev N=51 | B.06.01 | Overall change/physician | | Komed^®^ (sulfur + salicylic acid + resorcinol) Komed^®^ - proprietary 6 Komed^®^ better than proprietary 7 Komed^®^ worse than proprietary 4 Komed^®^ - placebo 13 Komed^®^ better than proprietary 21 | Placebo Komed^®^ - proprietary 0 Komed^®^ better than proprietary 0 Komed^®^ worse than proprietary 0 Komed^®^ -placebo 13 Komed^®^ better than proprietary 21
| | | | Komed^®^ worse proprietary 0 | Komed^®^ worse proprietary 0
191 ↑ Parallel split face Mild/mod/sev N=51 | B.06.02 | Overall change/physician | | Komed^®^ (sulfur + salicylic acid + resorcinol) Komed^®^ - proprietary 6 Komed^®^ better than proprietary 7 Komed^®^ worse than proprietary 4 Komed^®^ - placebo 13 Komed^®^ better than proprietary 21 | Proprietary formula (sulfur + salicylic acid + re) Komed^®^ - proprietary 6 Komed^®^ better than proprietary 7 Komed^®^ worse than proprietary 4 Komed^®^ -placebo 0 Komed^®^ better than proprietary 0
| | | | Komed^®^ worse proprietary 0 | Komed^®^ worse proprietary 0
165 ↑ Parallel split face Mild/mod N=25 | B.07.01 | Overall change | Mid (8) | Aluminum chloride Improved 10 No difference 3 Worse 10 | Vehicle Improved 3 No difference 4 Worse 16 | NS
228 Parallel N=776 | B.07.02 | Overall change/physician | Short (5) | Aluminum chlorhydroxide + sulfur Improved 142 Not improved 59 | Vehicle Improved 76 Not improved 75 | 0.001
176 ↓ Parallel Mod/sev N=150 | B.07.04 | Local effects | | Gluconolactone Dryness, scaling, burning, stinging, redness 11 None 34 | Vehicle Dryness, scaling, burning, stinging, redness 5 None 41

TRIAL: ↑↓ -presence of positive or negative methodological features (see Summary Table). “Mild/mod,” etc., -our assessment of entry severity of study patients. “P”- to parallel study, “S”-split face design. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table C1. Articles/arms for class ANTI-BACTERIAL (TOPICAL)

Comp-Trial | | TARGET | | HEADING | | COMPARATOR | | Outcome Table(s)
Comp-Trial | | Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment | Outcome Table(s)
C.01.01 | 20 | Clindamycin phosphate | 1 % topical bid. | Non-medicated soap and shampoo. | Vehicle | No dose information | pH adjusted to 6.7. Non-medicated soap and shampoo. | Continuous Discrete
| | Clindamycin hydrochloride | 1 % topical bid. | Non-medicated soap and shampoo. | Vehicle | No dose information | pH adjusted to 6.7. Non-medicated soap and shampoo. | Continuous Discrete
| 33 | Vehicle Clindamycin | No dose information. No dose information. | Clindamycin pH adjusted. | Vehicle Vehicle | No dose information. No dose information. | | Continuous Discrete
| 99 | Clindamycin phosphate | 1 % topical bid. | | Placebo | No dose information | Purpose^®^ soap before applying placebo. | Continuous
| | Clindamycin phosphate | 1 % topical bid. | | Placebo | No dose information | Purpose^®^ soap before applying placebo. | Continuous
| 144 | Clindamycin phosphate | 1 % topical bid. | Vehicle water. Active treatment including oval anti-bacterial and retinoic acid.. | Vehicle | No dose information | Active treatment, including oral anti-bacterial and retinoic acid.. | Discrete
| 199 | Clindamycin phosphate | 1 % topical bid. | Purpose^®^ soap (bar). | Vehicle | 4.3 g topical bid. | Dose given on per one week basis. Purpose^®^ soap (bar). | Continuous Discrete
| 217 | Clindamycin | No dose information. | | Vehicle | No dose information | | Continuous
| 327 | Clindamycin hydrochloride | No dose information. | | Vehicle | No dose information | | Continuous Discrete
C.01.02 | 305 | Clindamycin | 1 % topical bid. | Ivory^®^ soap; Suave^®^ shampoo. | Nicotinamide | 4 % topical bid. | Ivory^®^ soap; Suave^®^ shampoo. | Continuous Discrete
C.01.03 | 20 | Clindamycin phosphate | 1 % topical bid. | Non-medicated soap and shampoo. | Clindamycin hydrochloride | 1 % topical bid. | Non-medicated soap shampoo. | Continuous Discrete
| | Clindamycin hydrochloride | 1 % topical bid. | Non-medicated soap and shampoo. | Clindamycin phosphate | 1 % topical bid. | Non-medicated soap and shampoo. | Continuous Discrete
| 99 | Clindamycin phosphate | 1 % topical bid. | | Clindamycin phosphate | 1 % topical bid. | | Continuous
| | Clindamycin phosphate | 1 % topical bid. | | Clindamycin phosphate | 1 % topical bid. | | Continuous
| 131 | Clindamycin | 1 % topical bid. | Purpose^®^ soap. | Clindamycin | 1 % topical bid. | Purpose^®^ soap. | Continuous Discrete
| | Clindamycin | 1 % topical bid. | Purpose^®^ soap. | Clindamycin | 1 % topical bid. | Purpose^®^ soap. | Continuous Discrete
| 143 | Clindamycin hydrochloride | 1 % topical (can't say) | | Clindamycin phosphate | 1 % topical (can't say) | | Continuous
| | Clindamycin phosphate | 1 % topical (can't say) | | Clindamycin hydrochloride | 1 % topical (can't say) | | Continuous
| 229 | Clindamycin hydrochloride | 2 % topical bid. | Wash with sulfatic sulfactoral soap (Acne Aid^®^), apply hot facial pack with washcloth, then apply formulation. | Clindamycin phosphate | 2 % topical bid. | Wash with sulfatic sulfactoral soap (Acne Aid^®^), apply hot facial pack with washcloth, then apply formulation. | Continuous (M)
| 267 | Clindamycin | 1 % topical bid. | Purpose^®^ soap. | Clindamycin | 1 % topical bid. | Purpose^®^ soap. | Continuous Discrete
| | Clindamycin | 1 % topical bid. | Purpose^®^ soap. | Clindamycin | 1 % topical bid. | Purpose^®^ soap. | Continuous Discrete
C.01.04 | 158 | Clindamycin phosphate | 1 % topical bid. | Patients were instructed to wash face with Purpose^®^ soap pat the area dry with a towel, and wait 20 minutes before applying the study medication. Purpose^®^ soap. | Erythromycin | 2 % topical bid. | | Continuous Discrete
| 208 | Clindamycin phosphate | 1 topical bid. | | Erythromycin | 2 topical bid. | | Continuous Discrete
| 244 | Clindamycin | 1 % topical bid. | Morning and bedtime. Purpose^®^ soap. | Erythromycin | 2 % topical bid. | Morning and bedtime. Purpose^®^ soap. | Continuous Discrete
| 303 | Clindamycin | 1 % topical bid. | Alpha Keri^®^-soap. | Erythromycin | 1.5 % topical bid. | Alpha Keri^®^-soap. | Continuous Discrete
| 326 | Clindamycin | 1.5 % topical bid. | If side effect present, treatment changed to once a day. Alpha Keri^®^-mild soap. | Erythromycin | 1.5 % topical bid. | If side effect present then treatment was once a day. Alpha Keri^®^-mild soap. | Continuous Discrete
| | Clindamycin | 1.5 % topical bid. | If side effect present, treatment changed to once a day. Alpha Keri^®^-mild soap. | Erythromycin | 1.5 % topical bid. | If side effect present then treatment was once a day. Alpha Keri^®^-mild soap. | Continuous Discrete
C.01.05 | 261 | Clindamycin | 1 % topical bid. | Acne Aid^®^ soap, Johnson^®^'s baby shampoo. | Tetracycline hydrochloride | No dose information | | Continuous Discrete
C.01.05 | 291 | Clindamycin | 1 % topical bid. | Applied after washing. | Tetracycline | No dose information | Applied after washing. | Continuous Discrete
C.01.06 | 324 | Clindamycin phosphate | 1 % topical bid. | Cetaphil^®^ lotion - non-medicated lipid free cleanser bid. | Benzoyl peroxide | 5 % topical bid. | Cetaphil^®^ lotion - non-medicated lipid free cleanser bid. | Continuous
| 329 | clindamycin phosphate | 1 % topical bid. | | Benzoyl Peroxide | 5 5 topical bid. | | Continuous
C.02.03 | 214 | Benzoyl peroxide Clindamycin | 5 % topical qhs. 1 % topical qhs. | | Benzoyl peroxide | 5 % topical qhs. | | Continuous (M) Discrete
| 329 | Benzoyl Peroxide Clindamycin phosphate | 5 % topical qd. 1 % topical qd. | BP in am; CP in evening. Non-medicated mild soap.. | Benzoyl Peroxide | 5 5 topical bid. | | Continuous
C.03.01 | 39 | Erythromycin | 1.5 % topical bid. | Vehicle propylene glycol laureth. | Erythromycin base | No dose information | Vehicle propylene glycol laureth. | Continuous Discrete
| 89 | Erythromycin | 1.5 % topical bid. | Vehicle Laureth. | Placebo | No dose information | Vehicle Laureth −4. | Continuous Discrete
| 157 | Erythromycin | 1 % topical bid. | Vehicle. | Vehicle | No dose information. | Vehicle. | Continuous Discrete
| 184 | Erythromycin | 1.5 ml topical bid. | Culic acid .047, 20% preparation, 170 micogram/sq cm. Non-medicated soap and shampoo. | Vehicle | 1.5 ml topical bid. | Non-medicated soap and shampoo. | Continuous Discrete
| 205 | Erythromycin | 2 % topical bid. | Applied medication under supervision at initial visit. | Vehicle | No dose information | Applied medication under supervision at initial visit. | Continuous Discrete
| 274 | Erythromycin | 2 % topical bid. | Non-medicated soap. | Vehicle | No dose information | Non-medicated soap. | Continuous
| 277 | Erythromycin | 2 % topical bid. | Vehicle's brand name is Neutrogena Vehicle/N. Neutrogena^®^ Unscented soap. | Vehicle | No dose information | Neutrogena^®^ Unscented soap. | Continuous Discrete
| 285 | Erythromycin | 1.5 % topical bid. | | Vehicle | No dose information | | Continuous Discrete
C.03.025 | 39 | Erythromycin | 1.5 % topical bid. | Vehicle propylene glycol laureth. | Benzoyl Peroxide | 5 % topical bid. | | Continuous Discrete
C.04.01 | 151 | Fusidin | 2 % topical (can't say) | | Vehicle | No dose information. | | Continuous Discrete
| 315 | Fusidin | 2 % topical bid. | | Placebo | No dose information | | Continuous
C.05.005 | 194 | Meclocycline sulfosalicylate | 1 % topical bid. | Mild soap & shampoo supplied.. | Vehicle | No dose information | Vehicle cream. Meoclocycline vehicle. Mild soap & shampoo supplied/. | Continuous Discrete
| 195 | Meclocycline sulfosalicylate | 1 % topical qd. | | Placebo | No dose information | | Continuous Discrete
C.05.01 | 30 | Meclocycline | 1 % topical bid. | A.M. Only for first week; wash off after 3 hrs. For first 3 weeks. | Benzoyl peroxide | 5 % topical bid. | A.M. Only for first week; wash off after 3 hrs for for first 3 weeks. | Continuous Discrete
C.06.01 | 328 | Metronidazole | 0.75 % topical (can't say) | | Placebo | No dose information | | Continuous Discrete
C.07.01 | 287 | Neomycin | 0.5 % topical bid. | | Sulphur Hydrocortisone F Resorcinol Neomycin | 2.7 % topical bid. 0.5 % topical bid. 1.5 % topical bid. 0.5 % topical bid. | Bland soap. | Discrete (M)
C.08.01 | 10 | Placebo Tetracycline | 250 mg oral bid. 0.5 % topical bid. | | Placebo Vehicle | 250 mg oral bid. No dose information. | | Continuous Discrete
| 23 | Placebo Tetracycline hydrochloride | No dose information. 0.5 % topical (can't say) | Non-antibacterial soap and shampoo. | Placebo Placebo | No dose information No dose information | Non-antibacterial soap and shampoo. | Continuous
| 313 | Placebo Tetracycline hydrochloride | No dose information. 0.5 % topical bid. | 0.5% tetracycline = 0.22% tetracycline hcl + 0.28% 4-epi-tracycline HCl. Non-antibacterial soaps and shampoo. | Placebo Placebo | No dose information No dose information | Non-antibacterial soaps and shampoo. | Continuous
C.08.03 | 255 | Placebo Tetracycline | No dose information. No dose information. | | Placebo Benzoyl peroxide | No dose information. 5 % topical qd. | | Continuous Discrete
C.09.01 | 114 | Triclosan | No dose information. | Non-medicated soap. | Vehicle | No dose information. | Non-medicated soap. | Continuous
C.09.02 | 21 | Triclosan | No dose information. | The vehicle is a surface cleanser; the active drug is an antibacterial agent; trichlorohydroxyliphenylether. | Unknown | No dose information. | This is a combination antibacterial and detergent. | Discrete
C.09.03 | 114 | Propylene phenoxetol Triclosan | 0.75 % topical bid. 0.1 % topical bid. | | Vehicle | No dose information | Non-medicated soap. | Continuous

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table C2. CONTINUOUS outcomes for class ANTI-BACTERIAL (TOPICAL)

Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Target | | Comparator | | Between P-value
Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Data Type: Mean (SD) | Within P | Data Type: Mean(SD) | Within P | Between P-value
217 ↑ Parallel | N=42 Mod | C.01.01 | Closed comedones (count) Baseline counts: 44 (Target)/39 (Comparator) | Mid (12) | Clindamycin Percent Change*: −25 | NS | Vehicle Percent Change*: −31 | NS | NS
| | | Open comedones (count) Baseline counts: 30 (Target)/13 (Comparator) | Mid (12) | Percent Change*: −34 | .01 | Percent Change*: 64 | NS | NS
| | | Papules (count) Baseline counts: 33 (Target)/40 (Comparator) | Mid (12) | Percent Change*: −36 | .01 | Percent Change*: −38 | .02 | NS
| | | Pustules (count)Baseline counts: 9 (Target)/8 (Comparator) | Mid (12) | Percent Change*: −22 | NS | Percent Change*: −13 | NS | NS
| | | Severity (leeds) | Mid (12) | Measure: 1 | .01 | Measure: 1 | NS | NS
| | | Severity/flash photo (leeds) | Mid (12) | Measure: 2 | .03 | Measure: 1 | .04 | NS
| | | Severity/fluorescent photo-face+nose (leeds) | Mid (12) | Measure: 1 | NS | Measure: 1 | .001 | 0.02
| | | Severity/fluorescent photo-nose (leeds) | Mid (12) | Measure: 1 | .001 | Measure: 2 | NS | NS
| | | Severity/fluorescent photography | Mid (12) | Measure: 1 | .002 | Measure: 2 | NS | NS
99 ↓ Parallel | N=135 Mod | C.01.01 | Papules (count) Baseline counts: 21 (Target)/23 (Comparator) | Short (6) | Clindamycin phosphate (lotion) Percent Change*: −29 | | Placebo Percent Change*: −20 | | 0.05
| | | Pustules (count) Baseline counts: 4 (Target)/4 (Comparator) | Short (6) | Percent Change*: −46 | | Percent Change*: −35 | | NS
| | | Papules (count) Baseline counts: 21 (Target)/23 (Comparator) | Mid (12) | Percent Change*: −45 | | Percent Change*: −24 | | 0.05
| | | Pustules (count) Baseline counts: 4 (Target)/4 (Comparator) | Mid (12) | Percent Change*: −62 | | Percent Change*: −31 | | 0.05
33 Parallel | N=87 Mild | C.01.01 | Inflammatory (count) Baseline counts: 9 (Target)/7 (Comparator) | Short (6) | Clindamycin + vehicle Percent Change*: −68 | .0001 | Vehicle (oral) + vehicle (topical) Percent Change*: −12 | | NS*
33 Parallel | N=87 Mild | | Inflammatory (count) Between P-value: compared to tetra. Baseline counts: 9 (Target)/7 (Comparator) | Mid (8) | Percent Change*: −72 | .0001 | Percent Change*: −12 | NS | 0.0004
20 Parallel | N=358 Mod | C.01.01 | Papules (count) Baseline counts: 25 (Target)/26 (Comparator) | Short (6) | Clindamycin hydrochloride Percent Change*: −64 | | Vehicle Percent Change*: −166 | | 0.15
| | | Pustules (count) Baseline counts: 4 (Target)/4 (Comparator) | Short (6) | Percent Change*: −61 | | Percent Change*: −32 | | 0.018
327 Parallel | N=18 Mild/mod | | Nodules (count) Baseline counts: 2 (Target)/0 (Comparator) | Mid (8) | Percent Change*: −50 | NS | Percent Change*: 500 | NS | NS
| | | Papules (count) Baseline counts: 32 (Target)/31 (Comparator) | Mid (8) | Percent Change*: −43 | NS | Percent Change*: −23 | NS | NS
20 Parallel | N=358 Mod | | Papules change (count) Baseline counts: 25 (Target)/26 (Comparator) | Mid (8) | Percent change*: −66 | | Percent change*: −42 | | 0.0022
327 Parallel | N=18 Mild/mod | | Pustules (count) Baseline counts: 2 (Target)/1 (Comparator) | Mid (8) | Percent Change*: −56 | NS | Percent Change*: −86 | NS | NS
20 Parallel | N=358 Mod | | Pustules change (count) Baseline counts: 4 (Target)/4 (Comparator) | Mid (8) | Percent change*: −62 | | Percent change*: −43 | | 0.029
199 ↑ Parallel | N=45 Mild/mod | C.01.01 | Closed comedones (count) Baseline counts: 6 (Target)/8 (Comparator) | Short (3) | Clindamycin phosphate Percent Change*: 00 | NS | Vehicle Percent Change*: −17 | NS | NS*
| | | Nodes+cysts (count) Baseline counts: 1 (Target)/1 (Comparator) | Short (3) | Percent Change*: −17 | sig | Percent Change*: −50 | sig | NS
| | | Open comedones (count) Baseline counts: 9 (Target)/6 (Comparator) | Short (3) | Percent Change*: −09 | sig | Percent Change*: 03 | NS | NS*
| | | Papules (count) Between P-value: no P value given. Baseline counts: 21 (Target)/20 (Comparator) | Short (6) | Percent Change*: −39 | sig | Percent Change*: −37 | sig | NS
20 Parallel | N=358 Mod | | Papules (count) Baseline counts: 26 (Target)/26 (Comparator) | Short (6) | Percent Change*: −56 | | Percent Change*: −166 | | 0.15
| | | Pustules (count) Baseline counts: 4 (Target)/4 (Comparator) | Short (6) | Percent Change*: −68 | | Percent Change*: −32 | | 0.018
199 ↑ Parallel | N=45 Mild/mod | | Pustules (count) Baseline counts: 5 (Target)/4 (Comparator) | Short (6) | Percent Change*: −31 | sig | Percent Change*: −32 | sig | NS
20 Parallel | N=358 Mod | | Papules (count) Baseline counts: 26 (Target)/26 (Comparator) | Mid (8) | Percent Change*: −56 | | Percent Change*: −42 | | 0.0022
| | | Pustules change (count) Baseline counts: 4 (Target)/4 (Comparator) | Mid (8) | Percent change*: −72 | | Percent change*: −43 | | 0.029
199 ↑ Parallel | N=45 Mild/mod | | Closed comedones (count) Baseline counts: 6 (Target)/8 (Comparator) | Mid (12) | Percent Change*: −39 | NS | Percent Change*: −34 | NS | NS
| | | Nodes+cysts (count) Baseline counts: 1 (Target)/1 (Comparator) | Mid (12) | Percent Change*: −67 | sig | Percent Change*: −25 | sig | NS
| | | Open comedones (count) Baseline counts: 9 (Target)/6 (Comparator) | Mid (12) | Percent Change*: −63 | sig | Percent Change*: −17 | sig | NS
| | | Papules (count) Baseline counts: 21 (Target)/20 (Comparator) | Mid (12) | Percent Change*: −68 | sig | Percent Change*: −51 | sig | NS
| | | Pustules (count) Baseline counts: 5 (Target)/4 (Comparator) | Mid (12) | Percent Change*: −71 | sig | Percent Change*: −16 | sig | 0.021
99 ↓ Parallel | N=135 Mod | C.01.01 | Papules (count) Baseline counts: 22 (Target)/23 (Comparator) | Short (6) | Clindamycin phosphate (gel) Percent Change*: −36 | | Placebo Percent Change*: −20 | | 0.05
| | | Pustules (count) Baseline counts: 5 (Target)/4 (Comparator) | Short (6) | Percent Change*: −39 | | Percent Change*: −35 | | NS
| | | Papules (count) Baseline counts: 22 (Target)/23 (Comparator) | Mid (12) | Percent Change*: −49 | | Percent Change*: −24 | | 0.05
99 ↓ Parallel | N=135 Mod | | Pustules (count) Baseline counts: 5 (Target)/4 (Comparator) | Mid (12) | Percent Change*: −59 | | Percent Change*: −31 | | 0.05
305 ↓ Parallel | N=76 Mod | C.01.02 | Inflammatory change (%) | Short (4) | Clindamycin Percent change: −44 (32.) | | Nicotinamide Percent change: −30 (37.) | | NS
| | | Severity change (allen-smith %) | Short (4) | Measure: −27 (37.) | | Measure: −18 (24.) | | NS
| | | Inflammatory change (%) | Mid (8) | Percent change: −43 (41.) | | Percent change: −60 (41.) | | NS
| | | Severity (allen-smith) | Mid (8) | Measure: 3 (0.33) | | Measure: 2 (0.39) | | NS
| | | Severity change (allen-smith %) | Mid (8) | Measure: −38 (32.) | | Measure: −52 (32.) | | NS
99 ↓ Parallel | N=135 Mod | C.01.03 | Papules (count) Baseline counts: 21 (Target)/22 (Comparator) | Short (6) | Clindamycin phosphate (lotion) Percent Change*: −29 | | Clindamycin phosphate (gel) Percent Change*: −36 | | 0.05
| | | Pustules (count) Baseline counts: 4 (Target)/5 (Comparator) | Short (6) | Percent Change*: −46 | | Percent Change*: −39 | | NS
| | | Papules (count) Baseline counts: 21 (Target)/22 (Comparator) | Mid (12) | Percent Change*: −45 | | Percent Change*: −49 | | 0.05
| | | Pustules (count) Baseline counts: 4 (Target)/5 (Comparator) | Mid (12) | Percent Change*: −62 | | Percent Change*: −59 | | 0.05
267 ↓ Parallel | N=60 Mild | C.01.03 | Open comedones (count) Baseline counts: 8 (Target)/7 (Comparator) | Short (6) | Clindamycin (gel) Percent Change*: −37 | sig | Clindamycin (solution) Percent Change*: −39 | sig | NS*
| | | Pustules (count) Baseline counts: 5 (Target)/4 (Comparator) | Short (6) | Percent Change*: −53 | sig | Percent Change*: −48 | sig | NS*
| | | Open comedones (count) Baseline counts: 8 (Target)/7 (Comparator) | Mid (12) | Percent Change*: −68 | sig | Percent Change*: −61 | sig | NS*
| | | Pustules (count) Baseline counts: 5 (Target)/4 (Comparator) | Mid (12) | Percent Change*: −75 | sig | Percent Change*: −75 | sig | NS*
131 ↑ Parallel | N=70 Mod/sev | C.01.03 | Closed comedones (count) Baseline counts: 57 (Target)/39 (Comparator) | Short (6) | Clindamycin (lotion) Percent Change*: −19 | | Clindamycin (solution) Percent Change*: 04
| | | Open comedones (count) 6 Baseline counts: 10 (Target)/5 (Comparator) | Short (6) | Percent Change*: −22 | | Percent Change*: 14
| | | Papules (count) Baseline counts: 45 (Target)/42 (Comparator) | Short (6) | Percent Change*: −12 | | Percent Change*: −07
| | | Pustules (count) Baseline counts: 16 (Target)/25 (Comparator) | Short (6) | Percent Change*: −04 | | Percent Change*: −04
| | | Severity (goltz) | Short (6) | Measure: 2 (0.5) | | Measure: 2 (0.6) | | NS*
| | | Closed comedones (count) Baseline counts: 57 (Target)/39 (Comparator) | Mid (12) | Percent Change*: −50 | | Percent Change*: −22
| | | Open comedones (count) Baseline counts: 10 (Target)/5 (Comparator) | Mid (12) | Percent Change*: −61 | | Percent Change*: −46
| | | Papules (count) Baseline counts: 45 (Target)/42 (Comparator) | Mid (12) | Percent Change*: −30 | | Percent Change*: −28
| | | Pustules (count) Baseline counts: 16 (Target)/25 (Comparator) | Mid (12) | Percent Change*: −27 | | Percent Change*: −24
| | | Severity (goltz) | Mid (12) | Measure: 2 (0.5) | .01 | Measure: 2 (0.6) | .01 | NS*
267 ↓ Parallel | N=60 Mild | C.01.03 | Open comedones (count) Baseline counts: 7 (Target)/8 (Comparator) | Short (6) | Clindamycin (solution) Percent Change*: −39 | sig | Clindamycin (gel) Percent Change*: −37 | sig | NS*
| | | Pustules (count) Baseline counts: 4 (Target)/5 (Comparator) | Short (6) | Percent Change*: −48 | sig | Percent Change*: −53 | sig | NS*
| | | Open comedones (count) Baseline counts: 7 (Target)/8 (Comparator) | Mid (12) | Percent Change*: −61 | sig | Percent Change*: −68 | sig | NS*
| | | Pustules (count) Baseline counts: 4 (Target)/5 (Comparator) | Mid (12) | Percent Change*: −75 | sig | Percent Change*: −75 | sig | NS*
131 ↑ Parallel | N=70 Mod/sev | C.01.03 | Closed comedones (count) Baseline counts: 39 (Target)/57 (Comparator) | Short (6) | Clindamycin (solution) Percent Change*: 04 | | Clindamycin (lotion) Percent Change*: −19
| | | Open comedones (count) Baseline counts: 5 (Target)/10 (Comparator) | Short (6) | Percent Change*: 14 | | Percent Change*: −22
| | | Papules (count) Baseline counts: 42 (Target)/45 (Comparator) | Short (6) | Percent Change*: 07 | | Percent Change*: −12
| | | Pustules (count) Baseline counts: 25 (Target)/16 (Comparator) | Short (6) | Percent Change*: 04 | | Percent Change*: 04
| | | Severity (goltz) | Short (6) | Measure: 2 (0.6) | | Measure: 2 (0.5) | | NS*
| | | Closed comedones (count) Baseline counts: 39 (Target)/57 (Comparator) | Mid (12) | Percent Change*: −22 | | Percent Change*: −50
| | | Open comedones (count) Baseline counts: 5 (Target)/10 (Comparator) | Mid (12) | Percent Change*: −46 | | Percent Change*: −61
| | | Papules (count) Baseline counts: 42 (Target)/45 (Comparator) | Mid (12) | Percent Change*: −28 | | Percent Change*: −30
| | | Pustules (count) Baseline counts: 25 (Target)/16 (Comparator) | Mid (12) | Percent Change*: −24 | | Percent Change*: −27
| | | Severity (goltz) | Mid (12) | Measure: 2 (0.6) | .01 | Measure: 2 (0.5) | .01 | NS*
20 Parallel | N=358 Mod | C.01.03 | Papules (count) Baseline counts: 25 (Target)/26 (Comparator) | Short (6) | Clindamycin hydrochloride Percent Change*: −64 | | Clindamycin phosphate Percent Change*: −56 | | 0.15
| | | Pustules (count) Baseline counts: 4 (Target)/4 (Comparator) | Short (6) | Percent Change*: −61 | | Percent Change*: −68 | | 0.018
20 Parallel | N=358 Mod | | Papules change (count) Baseline counts: 25 (Target)/26 (Comparator) | Mid (8) | Percent change*: −66 | | Percent change*: −56 | | 0.0022
| | | Pustules change (count) Baseline counts: 4 (Target)/4 (Comparator) | Mid (8) | Percent change*: −62 | | Percent change*: −72 | | 0.029
143 ↑ Parallel | N=42 split face Sev | | Nodules (count) Baseline counts: 11 (Target)/9 (Comparator) | Mid (12) | Percent Change*: −100 | | Percent Change*: −78
| | | Papules (count) Baseline counts: 14 (Target)/14 (Comparator) | Mid (12) | Percent Change*: 221 | | Percent Change*: 214
| | | Pustules (count) Baseline counts: 214 (Target)/192 (Comparator) | Mid (12) | Percent Change*: −87 | | Percent Change*: −88
20 Parallel | N=358 Mod | C.01.03 | Papules (count) Baseline counts: 26 (Target)/25 (Comparator) | Short (6) | Clindamycin phosphate Percent Change*: −56 | | Clindamycin hydrochloride Percent Change*: −64 | | 0.15
| | | Pustules (count) Baseline counts: 4 (Target)/4 (Comparator) | Short (6) | Percent Change*: −68 | | Percent Change*: −61 | | 0.018
| | | Papules change (count) Baseline counts: 26 (Target)/25 (Comparator) | Mid (8) | Percent change*: −56 | | Percent change*: −66 | | 0.0022
| | | Pustules change (count) Baseline counts: 4 (Target)/4 (Comparator) | Mid (8) | Percent change*: −72 | | Percent change*: −62 | | 0.029
143 ↑ Parallel | N=42 split face Sev | | Nodules (count) Baseline counts: 9 (Target)/11 (Comparator) | Mid (12) | Percent Change*: −78 | | Percent Change*: −100
| | | Papules (count) Baseline counts: 14 (Target)/14 (Comparator) | Mid (12) | Percent Change*: 214 | | Percent Change*: 221 | | NS
| | | Pustules (count) Baseline counts: 192 (Target)/214 (Comparator) | Mid (12) | Percent Change*: −88 | | Percent Change*: −87
99 ↓ Parallel | N=135 Mod | C.01.03 | Papules (count) Baseline counts: 22 (Target)/21 (Comparator) | Short (6) | Clindamycin phosphate (gel) Percent Change*: −36 | | Clindamycin phosphate (lotion) Percent Change*: −29 | | 0.05
| | | Pustules (count) Baseline counts: 5 (Target)/4 (Comparator) | Short (6) | Percent Change*: −39 | | Percent Change*: −46 | | NS
| | | Papules (count) Baseline counts: 22 (Target)/21 (Comparator) | Mid (12) | Percent Change*: −49 | | Percent Change*: −45 | | 0.05
| | | Pustules (count) Baseline counts: 5 (Target)/4 (Comparator) | Mid (12) | Percent Change*: −59 | | Percent Change*: −62 | | 0.05
326 Parallel | N=72 Mod/sev | C.01.04 | Closed comedones (count) Count location: Both sides. Baseline counts: 28 (Target)/22 (Comparator) | Short (4) | Clindamycin Percent Change*: −24 | | Erythromycin Percent Change*: −18 | | NS*
| | | Closed comedones (count) | Short (4) | Percent Change*: −24 | | Percent Change*: −18 | | NS*
303 Parallel | N=178 Mod | | Inflammatory (count) Count location: Entire face. Baseline counts: 20 (Target)/22 (Comparator) | Short (4) | Percent Change*: −40 | | Percent Change*: −35 | | Duncan
326 Parallel | N=72 Mod/sev | | Non-inflammatory (count) Count location: Both sides. Baseline counts: 47 (Target)/58 (Comparator) | Short (4) | Percent Change*: −24 | | Percent Change*: −38 | NS | NS*
303 Parallel | N=178 Mod | | Non-inflammatory (count) Count location: Entire face. Baseline counts: 56 (Target)/53 (Comparator) | Short (4) | Percent Change*: −37 | | Percent Change*: −27 | | Duncan
326 Parallel | N=72 Mod/sev | | Non-inflammatory (count) Count location: Both sides. Baseline counts: 47 (Target)/58 (Comparator) | Short (4) | Percent Change*: −24 | | Percent Change*: −38 | NS | NS*
244 ↑ Parallel | N=120 Mild/mod | | Papules change (%) | Short (4) | Percent change: −28 | | Percent change: −33
| | | Pustules change (%) | Short (4) | Percent change: −37 | | Percent change: −61
326 Parallel | N=72 Mod/sev | | Total inflammatory (count) Count location: Both sides. Baseline counts: 23 (Target)/22 (Comparator) | Short (4) | Percent Change*: −31 | | Percent Change*: −22 | | NS*
326 Parallel | N=72 Mod/sev | | Total inflammatory (count) Count location: Both sides. Baseline counts: 23 (Target)/22 (Comparator) | Short (4) | Percent Change*: −31 | | Percent Change*: −22 | | NS*
244 ↑ Parallel | N=120 Mild/mod | | Comedones change (%) | Mid (8) | Percent change: −10 | | Percent change: −15
| | | Dryness change (score) | Mid (8) | Measure: 0 | | Measure: 0
| | | Dryness change (score) | Mid (8) | Measure: 0 | | Measure: 0
| | | Erythema change (score) | Mid (8) | Measure: 0 | | Measure: 0
| | | Inflammatory change (%) | Mid (8) | Percent change: −37 | | Percent change: −49
| | | Total lesions change (%) | Mid (8) | Percent change: −27 | | Percent change: −31
326 Parallel | N=72 Mod/sev | | Closed comedones (count) Count location: Both sides. Baseline counts: 28 (Target)/22 (Comparator) | Mid (12) | Percent Change*: −26 | .0006 | Percent Change*: 00 | NS | 0.0213
| | | Closed comedones (count) | Mid (12) | Percent Change*: −26 | .0006 | Percent Change*: 00 | NS | 0.0213
303 Parallel | N=178 Mod | | Inflammatory (count) Count location: Entire face. Baseline counts: 20 (Target)/22 (Comparator) | Mid (12) | Percent Change*: −59 | .001 | Percent Change*: −62 | .001 | Duncan
326 Parallel | N=72 Mod/sev | | Nodes+cysts (count) Count location: Both sides. Baseline counts: 2 (Target)/2 (Comparator) | Mid (12) | Percent Change*: −41 | NS | Percent Change*: −40 | NS | NS
| | | Nodes+cysts (count) | Mid (12) | Percent Change*: −41 | NS | Percent Change*: −40 | NS | NS
| | | Non-inflammatory (count) Count location: Both sides. Baseline counts: 47 (Target)/58 (Comparator) | Mid (12) | Percent Change*: 00 | .03 | Percent Change*: 00 | NS | NS
303 Parallel | N=178 Mod | | Non-inflammatory (count) Count location: Entire face. Baseline counts: 56 (Target)/53 (Comparator) | Mid (12) | Percent Change*: −39 | .001 | Percent Change*: −43 | .001 | Duncan
326 Parallel | N=72 Mod/sev | | Non-inflammatory (count) Count location: Both sides. Baseline counts: 47 (Target)/58 (Comparator) | Mid (12) | Percent Change*: 00 | .03 | Percent Change*: 00 | NS | NS
| | | Open comedones (count) Count location: Both sides. Baseline counts: 20 (Target)/37 (Comparator) | Mid (12) | Percent Change*: −55 | NS | Percent Change*: −52 | NS | NS
326 Parallel | N=72 Mod/sev | | Open comedones (count) Count location: Both sides. Baseline counts: 20 (Target)/37 (Comparator) | Mid (12) | Percent Change*: −55 | NS | Percent Change*: −52 | NS | NS
| | | Total inflammatory (count) Count location: Both sides. Baseline counts: 23 (Target)/22 (Comparator) | Mid (12) | Percent Change*: −01 | .0001 | Percent Change*: 00 | .0001 | NS
| | | Total inflammatory (count) | Mid (12) | Percent Change*: −01 | .0001 | Percent Change*: 00 | .0001 | NS
| | | Total lesions (count) Count location: Both sides. | Mid (12) | Raw count: 37 | .003 | Raw count: 45 | .01 | NS
| | | Total lesions (count) | Mid (12) | Raw count: 37 | .003 | Raw count: 45 | .01 | NS
158 ↑ Parallel | N=120 Mod | C.01.04 | Comedones (count) Baseline counts: 34 (Target)/29 (Comparator) | Short (4) | Clindamycin phosphate Percent Change*: −05 | | Erythromycin Percent Change*: −11
| | | Cysts change (%) | Short (4) | Percent change: 0 | | Percent change: 0
| | | Inflammatory (count) | Short (4) | Raw count: 18 | | Raw count: 15
| | | Total lesions change (%) | Short (4) | Percent change: 50 | | Percent change: 41
| | | Comedones change (%) Count location: Face. | Mid (8) | Percent change: 15 | | Percent change: −15 | | NS
| | | Cysts change (%) | Mid (8) | Percent change: 0 | | Percent change: 0
| | | Inflammatory change (%) Count location: Face. | Mid (8) | Percent change: −9 | | Percent change: −39 | | 0.003
| | | Overall change/investigator | Mid (8) | Measure: 56 | | Measure: 80 | | 0.012
| | | Total lesions change (%) Count location: Face. | Mid (8) | Percent change: −9 | | Percent change: −29
| | | Total lesions change (count) Baseline counts: 57 (Target)/53 (Comparator) | Mid (8) | Percent change*: 85 | | Percent change*: 75 | | 0.0183
291 ↑ Parallel | N=92 Mild | C.01.05 | Open comedones change (count) Baseline counts: 7 (Target)/7 (Comparator) | Short (6) | Clindamycin Percent change*: −30 | | Tetracycline Percent change*: 70 | | NS
291 ↑ Parallel | N=92 Mild | | Papules change (count) Baseline counts: 13 (Target)/13 (Comparator) | Short (6) | Percent change*: −61 | | Percent change*: −60 | | NS
| | | Pustules change (count) Baseline counts: 6 (Target)/6 (Comparator) | Short (6) | Percent change*: −64 | | Percent change*: −56 | | NS
| | | Open comedones change (count) Baseline counts: 7 (Target)/7 (Comparator) | Mid (8) | Percent change*: −28 | | Percent change*: 57 | | NS
| | | Papules change (count) Baseline counts: 13 (Target)/13 (Comparator) | Mid (8) | Percent change*: −71 | | Percent change*: −63 | | NS
| | | Pustules change (count) | Mid (8) | Measure: −4 | | Measure: −4 | | NS
261 ↓ Parallel | N=52 Mild/mod | C.01.05 | Total lesions (count) Count location: Both sides. | Short (6) | Clindamycin Raw count: 7 | | Tetracycline hydrochloride Raw count: 13
| | | Total lesions (count) | Mid (8) | Raw count: 6 | | Raw count: 14
329 Parallel | N=79 Mod | C.01.06 | Comedones (count) Count location: Unspecified. Baseline counts: 61 (Target)/43 (Comparator) | Short (6) | Clindamycin Percent Change*: −02 | | Benzoyl Peroxide Percent Change*: −19
| | | Cysts (count) Count location: Unspecified. | Short (6) | Raw count: 1 | | Raw count: 3
| | | Irritancy (score) Between P-value: C < B. | Short (6) | Measure: 0 | | Measure: 1 | | NS
| | | Papules (count) Count location: Unspecified. Baseline counts: 21 (Target)/16 (Comparator) | Short (6) | Percent Change*: −38 | | Percent Change*: −19
| | | Pustules (count) Count location: Unspecified. Baseline counts: 8 (Target)/8 (Comparator) | Short (6) | Percent Change*: −25 | | Percent Change*: −63
| | | Severity change (michaelsson %) Count location: Unspecified. | Short (6) | Measure: −36 | | Measure: −42
329 Parallel | N=79 Mod | | Comedones (count) Count location: Unspecified. Baseline counts: 61 (Target)/43 (Comparator) | Mid (10) | Percent Change*: −15 | | Percent Change*: −19
| | | Cysts (count) Count location: Unspecified. | Mid (10) | Raw count: 0 | | Raw count: 1
| | | Irritancy (score) Between P-value: C < B. | Mid (10) | Measure: 0 | | Measure: 1 | | NS
| | | Papules (count) Count location: Unspecified. Baseline counts: 21 (Target)/16 (Comparator) | Mid (10) | Percent Change*: −45 | | Percent Change*: −59
| | | Pustules (count) Count location: Unspecified. Baseline counts: 8 (Target)/8 (Comparator) | Mid (10) | Percent Change*: −44 | | Percent Change*: −72
| | | Severity change (michaelsson %) Count location: Unspecified. | Mid (10) | Measure: −47 | | Measure: −59 | | 0.05
324 ↑ Parallel | N=60 Mod | C.01.06 | Local reactions/Oiliness | Short (1.) | Clindamycin phosphate Measure: 1 (1.2) | | Benzoyl peroxide Measure: 1 (1.2) | | 0.05
| | | Inflammatory change (%) | Short (4) | Percent change: −26 (6.6) | .01 | Percent change: −28 (6.4) | .01 | NS
| | | Local reactions/Dryness | Short (4) | Measure: 1 (2.7) | | Measure: 1 (2.7) | | 0.05
| | | Local reactions/Erythema | Short (4) | Measure: 1 | | Measure: 1 | | NS
| | | Local reactions/Oiliness | Short (4) | Measure: 1 (2.7) | | Measure: 1 (2.7) | | 0.05
| | | Local reactions/Peeling | Short (4) | Measure: 0 (3.1) | | Measure: 1 (3.1) | | 0.05
| | | Non-inflammatory change (%) | Short (4) | Percent change: −29 (12.) | .002 | Percent change: −32 (18.) | .001 | NS
| | | Total lesions change (%) | Short (4) | Percent change: −27 (16.) | .001 | Percent change: −31 (23.) | .001 | NS
| | | Inflammatory change (%) | Mid (12) | Percent change: −28 (7.6) | .006 | Percent change: −52 (11.) | .02 | NS
| | | Local reactions/Dryness | Mid (12) | Measure: 1 (1.2) | | Measure: 2 (1.2) | | NS
| | | Local reactions/Erythema | Mid (12) | Measure: 1 | | Measure: 1 | | NS
324 ↑ Parallel | N=60 Mod | | Local reactions/Peeling | Mid (12) | Measure: 1 (2.4) | | Measure: 1 (2.4) | | 0.05
| | | Non-inflammatory change (%) | Mid (12) | Percent change: −37 (16.) | .002 | Percent change: −63 (35.) | .001 | 0.001
| | | Total lesions change (%) | Mid (12) | Percent change: −34 (21.) | .001 | Percent change: −60 (44.) | .001 | NS
329 Parallel | N=79 Mod | C.02.03 | Comedones (count) Count location: Unspecified. Baseline counts: 47 (Target)/43 (Comparator) | Short (6) | Clindamycin + Benzoyl Peroxide Percent Change*: −32 | | Benzoyl Peroxide Percent Change*: −19
| | | Cysts (count) Count location: Unspecified. | Short (6) | Raw count: 1 | | Raw count: 3
| | | Irritancy (score) Between P-value: C + B < B. | Short (6) | Measure: 0 | | Measure: 1 | | NS
| | | Papules (count) Count location: Unspecified. Baseline counts: 19 (Target)/16 (Comparator) | Short (6) | Percent Change*: −32 | | Percent Change*: −19
| | | Pustules (count) Count location: Unspecified. Baseline counts: 10 (Target)/8 (Comparator) | Short (6) | Percent Change*: −60 | | Percent Change*: −63
| | | Severity change (Michaelsson %) Count location: Unspecified. | Short (6) | Measure: −50 | | Measure: −42
| | | Comedones (count) Count location: Unspecified. Baseline counts: 47 (Target)/43 (Comparator) | Mid (10) | Percent Change*: −47 | | Percent Change*: −19
| | | Cysts (count) Count location: Unspecified. | Mid (10) | Raw count: 1 | | Raw count: 1
| | | Irritancy (score) Between P-value: C + B < B. | Mid (10) | Measure: 0 | | Measure: 1 | | NS
| | | Papules (count) Count location: Unspecified. Baseline counts: 19 (Target)/16 (Comparator) | Mid (10) | Percent Change*: −63 | | Percent Change*: −59
329 Parallel | N=79 Mod | | Pustules (count) Count location: Unspecified. Baseline counts: 10 (Target)/8 (Comparator) | Mid (10) | Percent Change*: −79 | | Percent Change*: −72
| | | Severity change (michaelsson %) Count location: Unspecified. | Mid (10) | Measure: −65 | | Measure: −59 | | 0.05
274 ↑ Parallel | N=187 Mild/mod | C.03.01 | Closed comedones (count) Baseline counts: 8 (Target)/3 (Comparator) | Short (4) | Erythromycin Percent Change*: −121 | | Vehicle Percent Change*: −133 | | NS
89 Parallel | N=253 Mod/sev | | Closed comedones change (%) Count location: Face. | Short (4) | Percent change: −10 | | Percent change: −20 | | NS
205 ↑ Parallel | N=225 Mild/mod | | Inflammatory (count) Baseline counts: 25 (Target)/24 (Comparator) | Short (4) | Percent Change*: −21 | | Percent Change*: −09 | | 0.004
274 | N=187 | | Open comedones (count) Baseline counts: 17 (Target)/15 (Comparator) | Short (4) | Percent Change*: −133 | | Percent Change*: −127 | | NS
89 Parallel | N=253 Mod/sev | | Open comedones change (%) Count location: Face. | Short (4) | Percent change: −22 | | Percent change: −18 | | NS
274 ↑ Parallel | N=187 Mild/mod | | Papules (count) Baseline counts: 16 (Target)/16 (Comparator) | Short (4) | Percent Change*: −129 | | Percent Change*: −113 | | 0.05
89 Parallel | N=253 Mod/sev | | Papules change (%) Count location: Face. | Short (4) | Percent change: −45 | | Percent change: −23 | | NS
285 | N=26 | | Papules change (%) Count location: Face unspecified. | Short (4) | Percent change: −55 | | Percent change: −27 | | 0.01
274 ↑ Parallel | N=187 Mild/mod | | Pustules (count) Baseline counts: 4 (Target)/4 (Comparator) | Short (4) | Percent Change*: −137 | | Percent Change*: −142 | | NS
89 Parallel | N=253 Mod/sev | | Pustules change (%) Count location: Face. | Short (4) | Percent change: −52 | | Percent change: −24 | | NS
285 | N=26 | | Pustules change (%) Count location: Face unspecified. | Short (4) | Percent change: −11 | | Percent change: −67
205 ↑ Parallel | N=225 Mild/mod | | Severity (cook) | Short (4) | Measure: 3 (1.) | | Measure: 4 (1.) | | 0.003
89 Parallel | N=253 Mod/sev | | Total lesions change (%) Count location: Face. | Short (4) | Percent change: −30 | | Percent change: −20 | | NS
184 ↑ Parallel | N=175 Mod | | Inflammatory (group count) Count location: Entire (with estimate). | Short (6) | Percent Change*: −99 | | Percent Change*: −99 | | 0.029
157 Parallel Mod/sev | N=29 split face | | Severity change (plewig) | Short (6) | Measure: −2 (0.7) | | Measure: −1 (0.6) | | NS*
274 ↑ Parallel | N=187 Mild/mod | | Closed comedones (count) Baseline counts: 8 (Target)/3 (Comparator) | Mid (8) | Percent Change*: −122 | | Percent Change*: −185 | | NS
| | | Open comedones (count) Baseline counts: 17 (Target)/15 (Comparator) | Mid (8) | Percent Change*: −144 | | Percent Change*: −131 | | 0.01
| | | Papules (count) Baseline counts: 16 (Target)/16 (Comparator) | Mid (8) | Percent Change*: −139 | | Percent Change*: −126 | | 0.05
| | | Pustules (count) Baseline counts: 4 (Target)/4 (Comparator) | Mid (8) | Percent Change*: −149 | | Percent Change*: −132 | | 0.05
89 Parallel | N=253 Mod/sev | | Closed comedones change (%) Count location: Face. | Mid (12) | Percent change: −25 | | Percent change: −20 | | NS
205 ↑ Parallel | N=225 Mild/mod | | Inflammatory (count) Baseline counts: 25 (Target)/24 (Comparator) | Mid (12) | Percent Change*: −46 | | Percent Change*: −19 | | 0.001
184 Parallel | N=175 Mod | | Inflammatory (group count) Count location: Entire (with estimate). | Mid (12) | Percent Change*: −99 | | Percent Change*: −99 | | 0.001
89 Parallel | N=253 Mod/sev | | Open comedones change (%) Count location: Face. | Mid (12) | Percent change: −30 | | Percent change: −20 | | NS
285 | N=26 | | Papules change (%) Count location: Face unspecified. | Mid (12) | Percent change: −71 | | Percent change: −43 | | 0.01
89 | N=253 | | Papules change (%) Count location: Face. | Mid (12) | Percent change: −55 | | Percent change: −45 | | 0.025
285 Parallel | N=26 Mod/sev | | Pustules change (%) | Mid (12) | Percent change: −78 | | Percent change: −53
89 | N=253 | | Pustules change (%) Count location: Face. | Mid (12) | Percent change: −64 | | Percent change: −50 | | NS
205 ↑ Parallel | N=225 Mild/mod | | Severity change (cook %) | Mid (12) | Measure: −40 (33.) | | Measure: −22 (36.) | | NS*
89 Parallel | N=253 Mod/sev | | Total lesions change (%) Count location: Face. | Mid (12) | Percent change: −40 | | Percent change: −30 | | 0.01
39 Parallel | N=94 Mild/mod/sev | C.03.01 | Inflammatory (counts) Count location: Unspecified. Between P-value: E<BP. | Short (4) | Erythromycin (topical) Measure: 12 (9.) | | Placebo Measure: 19 (14.) | | 0.01
| | | Non-inflammatory (count) Count location: Unspecified. Between P-value: E<BP. Baseline counts: 33 (Target)/32 (Comparator) | Short (4) | Percent Change*: −08 | | Percent Change*: −05 | | NS*
| | | Severity (Leeds) Count location: Unspecified. | Short (4) | Measure: 1 (0.33) | | Measure: 1 (0.38) | | 0.01
| | | Total Lesions (count) Count location: Unspecified. Between P-value: E>P. Baseline counts: 61 (Target)/59 (Comparator) | Short (4) | Percent Change*: −16 | | Percent Change*: 02 | | 0.01
| | | Inflammatory (count) Count location: Unspecified. Between P-value: E>P. Baseline counts: 20 (Target)/20 (Comparator) | Mid (8) | Percent Change*: −34 | | Percent Change*: −17 | | 0.01
| | | Non-inflammatory (count) Count location: Unspecified. Between P-value: E<BP. Baseline counts: 33 (Target)/32 (Comparator) | Mid (8) | Percent Change*: −10 | | Percent Change*: −02 | | NS*
| | | Severity (Leeds) Count location: Unspecified. | Mid (8) | Measure: 1 (0.27) | | Measure: 1 (0.32) | | 0.001
39 Parallel | N=94 Mild/mod/sev | | Total Lesions (count) Count location: Unspecified. Between P-value: E>P. Baseline counts: 61 (Target)/59 (Comparator) | Mid (8) | Percent Change*: −20 | | Percent Change*: 00 | | 0.01
39 Parallel | N=94 Mild/mod/sev | C.03.025 | Inflammatory (counts) Count location: Unspecified. Between P-value: E<BP. | Short (4) | Erythromycin (topical) Measure: 12 (9.) | | Benzoyl Peroxide Measure: 13 (9.) | | 0.01
| | | Non-inflammatory (count) Count location: Unspecified. Between P-value: E<BP. Baseline counts: 33 (Target)/33 (Comparator) | Short (4) | Percent Change*: −08 | | Percent Change*: −24 | | NS*
| | | Severity (Leeds) Count location: Unspecified. | Short (4) | Measure: 1 (0.33) | | Measure: 1 (0.27) | | 0.01
| | | Total Lesions (count) Count location: Unspecified. Between P-value: E>P. Baseline counts: 61 (Target)/63 (Comparator) | Short (4) | Percent Change*: −16 | | Percent Change*: −24 | | 0.01
| | | Inflammatory (count) Count location: Unspecified. Between P-value: E>P. Baseline counts: 20 (Target)/20 (Comparator) | Mid (8) | Percent Change*: −34 | | Percent Change*: −39 | | 0.01
| | | Non-inflammatory (count) Count location: Unspecified. Between P-value: E<BP. Baseline counts: 33 (Target)/33 (Comparator) | Mid (8) | Percent Change*: −10 | | Percent Change*: −29 | | NS*
| | | Severity (Leeds) Count location: Unspecified. | Mid (8) | Measure: 1 (0.27) | | Measure: 0 (0.33) | | 0.001
| | | Total Lesions (count) Count location: Unspecified. Between P-value: E>P. Baseline counts: 61 (Target)/63 (Comparator) | Mid (8) | Percent Change*: −20 | | Percent Change*: −31 | | 0.01
151 Parallel | N=79 Mild/mod | C.04.01 | Comedones (count) Count location: 5 cm diameter. Baseline counts: 7 (Target)/8 (Comparator) | Short (6) | Fusiden Percent Change*: −16 | | Vehicle Percent Change*: −31 | | NS
| | | Inflammatory (count) Count location: 5 cm diameter. Baseline counts: 11 (Target)/10 (Comparator) | Short (6) | Percent Change*: −62 | | Percent Change*: −36 | | 0.001
315 Parallel | N=56 | C.04.01 | Inflammatory change (%) | Short (4) | Fusidic acid Percent change: −13 (18.) | | Placebo Percent change: −20 (12.) | | NS
| | | Non-inflammatory change (%) | Short (4) | Percent change: 0 (20.) | | Percent change: 17 (20.) | | NS
| | | Severity change (leeds) | Short (4) | Measure: −20 (12.) | | Measure: −25 (10.) | | NS
| | | Inflammatory change (%) | Mid (12) | Percent change: −19 (25.) | | Percent change: −28 (18.) | | NS
| | | Non-inflammatory change (%) | Mid (12) | Percent change: −12 (20.) | | Percent change: 17 (30.) | | NS
| | | Severity change (leeds) | Mid (12) | Measure: −37 (15.) | | Measure: −30 (15.) | | NS
194 Parallel | N=134 Mod/sev | C.05.005 | Inflammatory change (median %) Count location: Face. | Short (5) | Meclocycline Measure: −49 | | Vehicle Measure: −26 | | 0.001
| | | Comedones (count) Count location: Face. Baseline counts: 88 (Target)/90 (Comparator) | Mid (11) | Percent Change*: −32 | | Percent Change*: −100
| | | Inflammatory change (median %) Count location: Face. | Mid (11) | Measure: −57 | | Measure: −22 | | 0.001
30 ↑ Parallel | N=102 Mod | C.05.01 | Comedones (count) Count location: Face. Baseline counts: 12 Target)/10 (Comparator) | Short (6) | Meclocycline Percent Change*: −26 | | Benzoyl peroxide Percent Change*: −58
30 ↑ Parallel | N=102 Mod | | Papules (count) Count location: Face. Baseline counts: 21 (Target)/21 (Comparator) | Short (6) | Percent Change*: −24 | | Percent Change*: −48
| | | Pustules (count) Count location: Face. Baseline counts: 9 (Target)/9 (Comparator) | Short (6) | Percent Change*: −28 | | Percent Change*: −56
| | | Comedones (count) Count location: Face. Baseline counts: 12 (Target)/10 (Comparator) | Mid (10) | Percent Change*: −30 | | Percent Change*: −68 | | 0.01
| | | Papules (count) Count location: Face. Baseline counts: 21 (Target)/21 (Comparator) | Mid (10) | Percent Change*: −33 | | Percent Change*: −62 | | NS
| | | Pustules (count) Count location: Face. Baseline counts: 9 (Target)/9 (Comparator) | Mid (10) | Percent Change*: −34 | | Percent Change*: −58 | | NS
328 ↑ Parallel | N=96 Mild/mod | C.06.01 | Inflammatory (count) Baseline counts: 24 (Target)/23 (Comparator) | Short (4) | Metronidazole Percent Change*: −06 | NS | Placebo Percent Change*: −03 | | NS
| | | Non-inflammatory (count) Baseline counts: 6 (Target)/8 (Comparator) | Short (4) | Percent Change*: 146 | NS | Percent Change*: 03 | NS | NS
| | | Inflammatory (count) Baseline counts: 24 (Target)/23 (Comparator) | Mid (12) | Percent Change*: −32 | NS | Percent Change*: −25 | NS | NS
| | | Non-inflammatory (count) Baseline counts: 6 (Target)/8 (Comparator) | Mid (12) | Percent Change*: −18 | NS | Percent Change*: −36 | NS | NS
C.08.01 | | | | Tetracycline (topical) + placebo (oral) | | | Vehicle (topical) + placebo (oral)
10 Parallel | N=60 Mod | | Severity (anderson) Count location: Butterfly. | Short (6) | Measure: 3 | NS | Measure: 4 | NS | NS
23 ↑ Parallel | N=75 Mod | C.08.01 | Severity change (cook) Count location: Entire face-(photos). | Short (6) | Tetracycline hydrochloride (topical) + placebo (oral) Measure: −1 (0.85) | | Placebo (topical) + placebo (oral) Measure: 0 (1.) | | 0.05
| | | Severity change (cook) | Long (13) | Measure: −1 (1.4) | | Measure: −1 (1.2) | | 0.05
313 ↑ Parallel | N=149 Mild/mod | C.08.01 | Severity (cook) Count location: Face. Between P-value: with respect to oral. | Short (4) | Tetracycline hydrochloride (topical) + placebo Measure: 3 | .05 | Placebo + placebo Measure: 4 | NS | NS
| | | Severity (cook) Count location: Face. Between P-value: with respect to oral. | Mid (12) | Measure: 2 | .05 | Measure: 3 | NS | NS
255 Parallel | N=69 Mod | C.08.03 | Back severity (leeds) Count location: Back. | Mid (12) | Tetracycline (topical) + placebo (oral) Measure: 0 (0.47) | NS | Benzoyl peroxide + placebo (oral) Measure: 0 (0.41) | NS | NS
| | | Chest severity (leeds) Count location: Chest. | Mid (12) | Measure: 0 (0.26) | NS | Measure: 0 (0.4) | NS | NS
| | | Face severity (leeds) Count location: Face. | Mid (12) | Measure: 0 | .01 | Measure: 1 | .001 | NS
| | | Inflammatory (count) Baseline counts: 65 (Target)/57 (Comparator) | Mid (12) | Percent Change*: −35 | .02 | Percent Change*: −42 | .001 | NS
| | | Non-inflammatory (count) | Mid (12) | Raw count: 43 | .003 | Raw count: 31 | .001 | NS
114 ↓ Parallel | N=72 Mild/mod | C.09.01 | Inflammatory (adjusted count) Count location: Entire face. | Short (4) | Triclosan Raw count: 14 (11.) | | Vehicle Raw count: 16 (11.) | | NS
| | | Inflammatory (score) | Short (4) | Measure: 2 | | Measure: 2 | | NS
| | | Non-inflammatory (count) | Short (4) | Raw count: 37 (11.) | | Raw count: 43 (11.) | NS | 0.05
| | | Overall change/patient (vas) | Short (4) | Measure: 2 | | Measure: 1
114 ↓ Parallel | N=72 Mild/mod | | Inflammatory (count) Count location: Entire face. Between P-value: with respect to vehicle. | Mid (8) | Raw count: 11 (11.) | | Raw count: 16 (11.) | | 0.05
| | | Inflammatory (score) Count location: Entire face. | Mid (8) | Measure: 1 | | Measure: 2 | | NS
| | | Non-inflammatory (count) | Mid (8) | Raw count: 34 (11.) | .05 | Raw count: 41 (11.) | NS | 0.01
| | | Overall change/patient (vas) | Mid (8) | Measure: 3 | | Measure: 2
114 ↓ Parallel | N=72 Mild/mod | C.09.03 | Inflammatory (adjusted count) Count location: Entire face. | Short (4) | Triclosan + propylene phenoxetol Raw count: 14 (9.) | | Vehicle Raw count: 16 (11.) | | NS
| | | Inflammatory (score) | Short (4) | Measure: 2 | | Measure: 2 | | NS
| | | Non-inflammatory (count) | Short (4) | Raw count: 35 (9.) | .01 | Raw count: 43 (11.) | NS | NS*
| | | Overall change/patient (vas) | Short (4) | Measure: 2 | | Measure: 1
| | | Inflammatory (count) Count location: Entire face. Between P-value: with respect to vehicle. | Mid (8) | Raw count: 12 (9.) | | Raw count: 16 (11.) | | 0.05
| | | Inflammatory (score) Count location: Entire face. | Mid (8) | Measure: 1 | | Measure: 2 | | NS
| | | Non-inflammatory (count) | Mid (8) | Raw count: 34 (9.) | .05 | Raw count: 41 (11.) | NS | 0.005
| | | Overall change/patient (vas) | Mid (8) | Measure: 3 | | Measure: 2

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., - our assessment of entry severity of study patients. “P”- parallel study, “S”- split face design. TARGET and COMPARATOR: “Percent change”- an outcome derived from individual final and baseline measures; “Percent change*”- we calculated a group-based percentage change; “Change” - raw difference from baseline; “Change*” - calculated change; “Measure” - an outcome measure with no baseline comparison. SD: standard deviation. WITHIN P: P-value with respect to baseline in one arm. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table C3: DISCRETE outcomes for class ANTI-BACTERIAL (TOPICAL)

Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Treatment | Comparator | Between P-value
Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Attribute: Number of patients | Attribute: Number of patients | Between P-value
| C.01.01 | | | Clindamycin + vehicle | Vehicle (oral) + vehicle (topical)
33 Parallel Mild N=87 | | Diarrhea | Mid (8) | Present 1 | Present 1
| | Overall change/patient | Mid (8) | Marked improvement 19 Improved 3 No change 7 Worse 0 | Marked improvement 0 Improved 1 No change 20 Worse 8
| | Overall change/physcian | Mid (8) | Excellent 17 Good 6 Fair 1 Poor 5 | Excellent 0 Good 0 Fair 4 Poor 25
| C.01.01 | | | Clindamycin hydrochloride | Vehicle
20 Parallel Mod N=358 | | Diarrhea | Mid (8) | Diarrhea due to medication 0 Diarrhea 6 No diarrhea 117 | Diarrhea due to medication 0 Diarrhea 2 No diarrhea 111
| | Overall change/patient | Mid (8) | Worse 2 No change 26 Improved 68 Markedly improved 27 | Worse 11 No change 38 Improved 52 Markedly improved 11 | 0.003
327 Parallel Mild/mod N=18 | | Diarrhea | | Diarrhea 0 | Diarrhea 0
| | Erythema | | Erythema 3 | Erythema 1
| | Itching | | Burning /itching 3 | Burning/itching 2
| | Peeling | | Peeling 3 | Peeling 2
| | Severity/patient | Mid (8) | Marked improvement 3 Some improvement 3 Slight improvement No change 3 | Marked improvement 1 Some improvement Slight improvement 4 No change
| C.01.01 | | | Clindamycin phosphate | Vehicle
20 Parallel Mod N=358 | | Diarrhea | Mid (8) | Diarrhea due to medication 1 Diarrhea 5 No diarrhea 109 | Diarrhea due to medication 0 Diarrhea 2 No diarrhea 111
| | Overall change/patient | Mid (8) | Worse 3 No change 13 Improved 76 Markedly improved 22 | Worse 11 No change 38 Improved 52 Markedly improved 11 | 0.003
199 ↑ Parallel Mild/mod N=45 | | Overall change/physician | Mid (12) | Much improved 8 Improved 11 No change 1 Worse 1 | Much improved 3 Improved 9 No change 2 Worse 0
| | Severe side effects | Mid (12) | Burning 0 Itching 1 | Burning 1 Itching 1
| C.01.02 | | | Clindamycin | Nicotinamide
305 ↓ Parallel Mod N=76 | | Overall change/physician | Short (4) | Much or moderately better 8 | Much or moderately better 8 | NS
| | Local side effects | Mid (8) | Local site reactions 9 | Local site reactions 10
| | Overall change/physician | Mid (8) | Much or moderately better 19 | Much or moderately better 18 | NS
| C.01.03 | | | Clindamycin (gel) | Clindamycin (solution)
267 ↓ Parallel Mild N=60 | | Side effects | | Mild diarrhea 1 Upset stomach 0 Flare-up of acne 2 Skin dryness 3 | Mild diarrhea 1 Upset stomach 1 Flare-up of acne 0 Skin dryness 9
| | Overall change/investigator | Mid (12) | Improved or markedly improved 25 Other 5 | Improved or markedly improved 27 Other 3
| | Overall change/patient | Mid (12) | Improved 23 Other 7 | Improved 28 Other 2
| C.01.03 | | | Clindamycin (lotion) | Clindamycin (solution)
131 ↑ Parallel Mod/sev N=70 | | Burning | Short (6) | Present 6 Absent 26 | Present 3 Absent 31
131 ↑ Parallel Mod/sev N=70 | | Dryness | Short (6) | Present 13 Absent 19 | Present 17 Absent 17
| | Erythema | Short (6) | Present 11 Absent 21 | Present 17 Absent 17
| | Itching | Short (6) | Present 7 Absent 25 | Present 3 Absent 31
| | Peeling | Short (6) | Present 9 Absent 23 | Present 5 Absent 29
| | Burning | Mid (12) | Present 2 Absent 30 | Present 3 Absent 31
| | Diarrhea | Mid (12) | Present 1 Absent 31 | Present 2 Absent 32
| | Dryness | Mid (12) | Present 13 Absent 19 | Present 19 Absent 15
| | Erythema | Mid (12) | Present 13 Absent 19 | Present 15 Absent 19
| | Itching | Mid (12) | Present 9 Absent 23 | Present 4 Absent 30
| | Overall change/patient | Mid (12) | Marked improvement 4 Improved 18 No change 9 Worse 1 | Marked improvement 5 Improved 18 No change 7 Worse 4
| | Overall change/physician | Mid (12) | Marked improvement 5 Improved 20 No change 6 Worse 1 | Marked improvement 5 Improvement 19 No change 9 Worse 1
| | Peeling | Mid (12) | Present 6 Absent 26 | Present 5 Absent 29
| C.01.03 | | | Clindamycin hydrochloride | Clindamycin phosphate
20 Parallel Mod N=358 | | Diarrhea | Mid (8) | Diarrhea due to medication 0 Diarrhea 6 No diarrhea 117 | Diarrhea due to medication 1 Diarrhea 5 No diarrhea 109
20 Parallel Mod N=358 | | Overall change/patient | Mid (8) | Worse 2 No change 26 Improved 68 Markedly improved 27 | Worse 3 No change 13 Improved 76 Markedly improved 22 | 0.003
| C.01.04 | | | Clindamycin | Erythromycin
303 Parallel Mod N=178 | | Inter-treatment preference/patient | Mid (12) | Excellent 63 Other 25 | Excellent 75 Other 5 | NS
| | Side effects | Mid (12) | Dropped out 0 Reduced dose 5 Other 12 None 69 | Dropped out 1 Reduced dose 10 Other 12 None 58
326 Parallel Mod/sev N=72 | | Overall change/patient | Mid (12) | Excellent + good 24 Other 12 | Excellent + good 25 Other 11 | NS
| | Overall change/patient | Mid (12) | Excellent + good 24 Other 12 | Excellent + good 25 Other 11 | NS
| C.01.04 | | | Clindamycin phosphate | Erythromycin
158 ↑ Parallel Mod N=120 | | Adverse reactions | Mid (8) | Erythema/blistering 1 Diarrhea/vomiting 1 Acne exacerbation 1 | Erythema/blistering 0 Diarrhea/vomiting 0 Acne exacerbation 0
| C.01.05 | | | Clindamycin | Tetracycline
291 ↑ Parallel Mild N=92 | | Severity assessment | Mid (8) | Poor 1 Fair 13 Good 25 Excellent 5 | Poor 11 Fair 10 Good 18 Excellent 4 | 0.02
| | Side effects Between P-value: burning .05 | Mid (8) | Itch 0 Irritation 0 Diarrhea 1 Vaginitis 1 | Itch 1 Irritation 1 Diarrhea 1 Vaginitis 0 | NS
| | | | Hematuria 1 | Hematuria 0
| C.01.05 | | | Clindamycin | Tetracycline hydrochloride
261 ↓ Parallel Mild/mod N=52 | | Erythema | Mid (8) | None 15 Mild 6 Moderate 1 | None 19 Mild 8 Moderate 0 | NS
| | Itching/burn | Mid (8) | None 22 Mild 1 Moderate 0 | None 23 Mild 4 Moderate 0 | NS
| | Overall improvement (discretized %) | Mid (8) | Good (67-100%) 10 Fair (34-66%) 10 Poor (<33%) 2 | Good (67-100%) 7 Fair (34-66%) 7 Poor (<33%) 13 | 0.01
| | Peeling | Mid (8) | None 22 Mild 1 | None 25 Mild 2 | NS
| | Side effects | Mid (8) | Diarrhea 2 Film of yellow discoloration 0 | Diarrhea 0 Film of yellow discoloration 26
| C.03.01 | | | Erythromycin | Vehicle
184 ↑ Parallel Mod N=175 | | Burning-irritation | Mid (12) | Mild 3 Moderate 0 Severe 0 | Mild 5 Moderate 6 Severe 1
| | Dryness | Mid (12) | Mild 3 Moderate 1 Severe 0 | Mild 3 Moderate 1 Severe 1
| | Exudate | Mid (12) | Moderate 1 | Moderate 0
| | Eye irritation | Mid (12) | Present 2 | Present 0
| | Herpes simplex | Mid (12) | Mild 1 | Mild 0
| | Oiliness | Mid (12) | Mild 1 | Mild 1
| | Overall change/physician | Mid (12) | Excellent 31 Good 21 Partially improved 17 Not improved 10 | Excellent 8 Good 12 Partially improved 25 Not improved 23 | 0.001
| | | | Worse 2 | Worse 7
| | Pruritis | Mid (12) | Mild 2 Not stated 1 | Mild 9 Not stated
184 ↑ Parallel Mod N=175 | | Redness | Mid (12) | Mild 4 Moderate 0 Severe 1 | Mild 6 Moderate 3 Severe 0
| | Scaling | Mid (12) | Mild 4 Moderate 2 Severe 0 | Mild 3 Moderate 4 Severe 1
| | Side effects | Mid (12) | Any (continued) 15 Any (withdraw) 2 | Any (continued) 17 Any (withdraw) 4
205 Parallel Mild/mod N=225 | | Erythema | Mid (12) | None 84 Mild 18 Moderate 2 Moderate severe 1 | None 82 Mild 18 Moderate 2 Moderate severe 1
| | | | Severe 0 | Severe 0
| | Peeling | Mid (12) | None 95 Mild 8 Moderate 2 Moderate severe 0 | None 96 Mild 5 Moderate 2 Moderate severe 0
| | | | Severe 0 | Severe 0
277 Parallel split face Mild/mod N=73 | | Lesions change | Mid (8) | Any change less than 0 51 50% or less change 21 | Any change less than 0 40 50% or less change 14 | NS
| C.04.01 | | | Fusiden | Vehicle
151 Parallel Mild/mod N=79 | | Side effects | Short (3) | Mild itching 1 Diffuse exanthema 0 None 35 | Mild itching 0 Diffuse exanthema 1 None 33
| C.05.01 | | | Meclocycline | Benzoyl peroxide
30 ↑ Parallel Mod N=102 | | Skin discoloration | Mid (10) | Present 2 Absent 31 | Present 1 Absent 35
| C.06.01 | | | Metronidazole | Placebo
328 ↑ Parallel Mild/mod N=96 | | Local irritation | | Present 2 Absent 46 | Present 1 Absent 47
| | Side effects | Mid (8) | Redness 0 Dryness 0 | Redness 0 Dryness 0
| C.08.01 | | | Tetracycline (topical) + placebo (oral) | Vehicle (topical) + placebo (oral)
10 Parallel Mod N=60 | | Severity change | Mid (8) | > 1 unit decrease 14 < 1 unit decrease 3 No change 2 | > 1 unit decrease 6 < 1 unit decrease 4 No change 7 | NS
| C.08.03 | | | Tetracycline (topical) + placebo (oral) | Benzoyl peroxide + placebo (oral)
255 Parallel Mod N=69 | | Side effects | Mid (12) | Severe facial reaction 0 GI symptoms 2 Vaginal candidiasis 0 | Severe facial reaction 1 GI symptoms 2 Vaginal candidiasis 1
| C.09.02 | | | Triclosan | Phisohex
21 Cross-over Mild/mod/sev N=34 | | Overall change/patient Between P-value: Where pt & doctor agreed, pref was for triclosan, p. 05 | Short (6) | Worse 6 No change 2 Some improvement 11 Marked improvement 12 | Worse 3 No change 11 Some change 11 Marked improvement 6 | NS
| | | | Not answered 2 | Not answered 2
| | Overall change/physician Between P-value: Where pt & doctor agreed, pref was for triclosan, p. 05 | Short (6) | No change 7 Some improvement 16 Marked improvement 6 Not answered 4 | No change 10 Some improvement 15 Marked improvement 6 Not answered 2 | NS
| | Side effects | Short (6) | Local drying/scaling/itching 11 Erythema/soreness (withdraw) 2 | Local drying/scaling/itching 9 Erythema/soreness (withdraw) 3

TRIAL:↑↓-presence of positive or negative methodological features (see Summary Table). “Mild/mod,” etc., -our assessment of entry severity of study patients. “P”- to parallel study, “S”-split face design. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table D1. Articles/arms for class ANTI-BACTERIAL (TOPICAL)/KERATOLYTIC (TOPICAL)

Comp-Trial | | TARGET | | HEADING | | COMPARATOR | | Outcome Table(s)
Comp-Trial | | Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment | Outcome Table(s)
D.01.01 | 97 | Benzoyl peroxide | 5.5 % topical (1 to 4 times daily) | Basis^®^. | Vehicle | No dose information. | Loroxide^®^ base. Basis^®^. | Continuous (M) Discrete
| 173 | Benzoyl peroxide | 5 % topical bid. | | Vehicle | No dose information. | | Continuous Discrete
| 176 | Benzoyl peroxide | 5 % topical (can't say) | | Vehicle | No dose information. | Vehicle of gluconolactone. | Continuous Discrete
| 241 | Benzoyl peroxide | 2.5 % topical bid. | Non-medicated soap. | Vehicle | No dose information. | Non-medicated soap. | Continuous
| 314 | Benzoyl peroxide | 20 % topical bid. | Application once daily in first week. | Vehicle | No dose information. | Application once daily in first week. | Continuous Discrete
D.01.03 | 176 | Benzoyl peroxide | 5 % topical (can't say) | | Gluconolactone | 14 % topical (can't say) | | Continuous Discrete
D.01.04 | 304 | Benzoyl peroxide | 10 % topical qd. | Wash affected area once or twice a day. | Salicylic acid | 2 % topical qd. | Wash affected area once or twice a day. | Continuous
D.01.05 | 272 | Benzoyl peroxide | No dose information. | | Resorcinol Sulphur | 3 % topical (can't say) 5 % topical (can't say) | | Continuous
D.01.09 | 76 | Benzoyl peroxide | 5 % topical (can't say) | | Benzoyl peroxide | 5 % topical (can't say) | | Continuous Discrete
| 118 | Benzoyl peroxide | 5 % topical bid. | Initially, daily washed off after 1-2 hrs.; advanced to bid after tolerated overnight x 3 nights | Benzoyl peroxide | 5 % topical bid. | Initially, daily washed off after 1-2 hrs; advanced to bid after tolerated overnight x 3 nights | Continuous Discrete
| 149 | Benzoyl peroxide | 5 % topical bid. | | Benzoyl peroxide | 10 % topical bid. | | Continuous (M) Discrete
| 221 | Benzoyl peroxide | 5 % topical qd. | 4 weeks 5%; 4 weeks 10%; once or twice/day. | Benzoyl peroxide | 5 % topical qd. | | Continuous Discrete
| 242 | Benzoyl peroxide | 2.5 % topical (can't say) | The 2.5% formulation vehicle was different from that of 5% bp. Non-medicated soap. | Benzoyl peroxide | 5 % topical bid. | The 5% bp different from that of 2.5% bp. Non-medicated soap. | Continuous
| 243 | Benzoyl peroxide | 2.5 % topical bid. | The 2.5% formulation vehicle was different from that of 10% bp. Non-medicated soap. | Benzoyl peroxide | 10 % topical bid. | Non-medicatedsoap. | Continuous Discrete
| 351 | Benzoyl peroxide | 2.5 % topical bid. | Soap. | Benzoyl peroxide | 5 % topical bid. | Soap. | Discrete
D.01.10 | 278 | Urea Benzoyl peroxide | 8 % topical bid. 5 % topical bid. | Combination lotion. | Benzoyl peroxide | 5 % topical bid. | | Continuous Discrete
D.03.01 | 310 | Zinc sulphur Glycolic acid Benzoyl peroxide | No dose information. No dose information. 10 % topical bid. | | Placebo | No dose information. | | Continuous Discrete
D.03.02 | 16 | Hydrocortisone Benzoyl peroxide Hydroxyquinolinne | 1 % topical tid. 10 % topical tid. 0.5 % topical tid. | Soap. | Benzoyl peroxide Hydroxyquinoline | 10 % topical tid. 0.5 % topical tid. | Soap. | Discrete
| 177 | Hydrocortisone Potassium hydroxyquinoline Benzoyl peroxide | 1 % topical bid. 0.5 % topical bid. 10 % topical bid. | | Potassium hydroxyquinoline Benzoyl peroxide | 0.5 % topical bid. 10.5 % topical bid. | | Continuous (M) Discrete
D.03.04 | 82 | Sulphur Benzoyl peroxide | 5 % topical bid. 10 % topical bid. | | Sulphur | 5 % topical bid. | | Discrete
D.04.01 | 214 | Benzoyl peroxide Clindamycin | 5 % topical qhs. 1 % topical qhs. | | Vehicle | No dose information | | Continuous (M) Discrete
D.05.01 | 310 | Erythromycin Benzoyl peroxide | 3 % topical bid. 5 % topical bid. | | Placebo | No dose information. | | Continuous Discrete
D.05.01 | 53 | Erythromycin | 3 % topical bid. | Combined product. | Benzoyl peroxide | 5 % topical bid. | | Continuous (M)
D.05.02 | 260 | Benzoyl peroxide Erythromycin | 5 % topical bid. 3 % topical bid. | | Clindamycin phosphate | No dose information. | | Continuous Discrete
D.05.03 | 310 | Erythromycin Benzoyl peroxide | 3 % topical bid. 5 % topical bid. | | Zinc sulphur Glycolic acid Benzoyl peroxide | No dose information. No dose information. 10 % topical bid. | | Continuous Discrete
D.05.04 | 62 | Erythromycin Benzoyl peroxide | 3 % topical bid. 5 % topical bid. | | Erythromycin Zinc | 4 % topical bid. 1.2 % topical bid. | | Continuous Discrete
D.06.01 | 30 | Benzoyl peroxide Meclocycline | 5 % topical qd. 1 % topical qd. | A.M. Only for first week; wash off after 3 hrs. For first 3 weeks. | Benzoyl peroxide | 5 % topical bid. | A.M. Only for first week; wash off after 3 hrs. For first 3 weeks. | Continuous Discrete
D.07.01 | 121 | Metronidazole Benzoyl peroxide | 2 % topical bid. 5 % topical bid. | | Vehicle | No dose information. | | Discrete
D.07.02 | 122 | Metronidazole Benzoyl peroxide | 2 % topical bid. 5 % topical bid. | | Benzoyl peroxide | 5 % topical bid. | | Discrete
D.08.01 | 85 | Benzoyl peroxide Miconazole | 5 % topical bid. 2 % topical bid. | Combination cream. | Benzoyl peroxide | 5 % topical bid. | | Continuous Discrete
| 111 | Miconazole Benzoyl peroxide | 2 % topical bid. 5 % topical bid. | | Benzoyl peroxide | 5 % topical bid. | | Continuous
| 231 | Miconazole Benzoyl peroxide | 2 % topical bid. 5 % topical bid. | Qhs 1st week. | Benzoyl peroxide | 5 % topical bid. | Qhs 1st week. | Continuous Discrete
D.08.02 | 335 | Miconazole nitrate Benzoyl peroxide | 2 % topical bid. 5 % topical bid. | | Benzoyl peroxide Isoconazole nitrate | 5 % topical qd. 1 % topical qd. | Isoconazole nitrate 1% application in the morning and 5% bp applied in the evening. | Continuous Discrete

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table D2. CONTINUOUS outcomes for class ANTI-BACTERIAL (TOPICAL)/KERATOLYTIC (TOPICAL)

Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Target | | Comparator | | Between P-value
Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Data Type: Mean (SD) | Within P | Data Type: Mean (SD) | Within P | Between P-value
173 ↑ Parallel | N=77 Mild/mod | D.01.01 | Inflammatory (count) Count location: Face. Baseline counts: 44 (Target)/44 (Comparator) | Short (4) | Benzoyl peroxide Percent Change*: −43 | | Vehicle Percent Change*: −05 | NS
176 ↓ Parallel | N=150 Mod/sev | | Inflammatory change (%) Count location: Face. | Short (4) | Percent change: −42 | | Percent change: −39 | | NS
173 ↑ Parallel | N=77 Mild/mod | | Non-inflammatory (count) Count location: Face. Baseline counts: 48 (Target)/49 (Comparator) | Short (4) | Percent Change*: −23 | .05 | Percent Change*: 02
176 ↓ Parallel | N=150 Mod/sev | | Non-inflammatory change (%) Count location: Face. | Short (4) | Percent change: −24 | | Percent change: −4 | | NS
173 ↑ Parallel | N=77 Mild/mod | | Severity (leeds) | Short (4) | Measure: 1 | .01 | Measure: 1 | NS | 0.01
176 ↓ Parallel | N=150 Mod/sev | | Total lesions change (%) | Short (4) | Percent change: −25 | | Percent change: −7
241 ↑ Parallel | N=50 Mild/mod | | Total lesions change (%) | Short (6) | Percent change: −44 | | Percent change: −3 | | 0.01
| | | Total lesions change (%) | Mid (8) | Percent change: −51 | | Percent change: −18 | | 0.01
173 | N=77 | | Inflammatory (count) Count location: Face. Baseline counts: 44 (Target)/44 (Comparator) | Mid (12) | Percent Change*: −52 | .01 | Percent Change*: 09 | NS | 0.01
176 ↓ Parallel | N=150 Mod/sev | | Inflammatory change (%) Count location: Face. | Mid (12) | Percent change: −60 | .05 | Percent change: −10 | NS | 0.05
173 ↑ Parallel | N=77 Mild/mod | | Non-inflammatory (count) Count location: Face. Baseline counts: 48 (Target)/49 (Comparator) | Mid (12) | Percent Change*: −52 | .01 | Percent Change*: 06 | NS | 0.01
176 ↓ Parallel | N=150 Mod/sev | | Non-inflammatory change (%) Count location: Face. | Mid (12) | Percent change: −30 | .02 | Percent change: −4 | NS | 0.05
173 ↑ Parallel | N=77 Mild/mod | | Severity (leeds) | Mid (12) | Measure: 0 | .01 | Measure: 1 | | 0.01
176 ↓ Parallel | N=150 Mod/sev | | Total lesions change (%) Count location: Face. | Mid (12) | Percent change: −31 | .02 | Percent change: −5 | NS | NS
314 Parallel | N=59 Mod | D.01.01 | Total lesion (count) Count location: Entire face. Baseline counts: 19 (Target)/16 (Comparator) | Short (6) | Benzoyl Peroxide (20%) Percent Change*: −58 | | Vehicle Percent Change*: −25
| | | Total lesion (count) | Mid (12) | Percent Change*: −53 | | Percent Change*: −25
176 ↓ Parallel | N=150 Mod/sev | D.01.03 | Inflammatory change (%) Count location: Face. | Short (4) | Benzoyl peroxide Percent change: −42 | | Gluconolactone Percent change: −49 | | NS
| | | Non-inflammatory change (%) | Short (4) | Percent change: −24 | | Percent change: −8 | | NS
| | | Total lesions change (%) | Short (4) | Percent change: −25 | | Percent change: −15
| | | Inflammatory change (%) | Mid (12) | Percent change: −60 | .05 | Percent change: −59 | .001 | 0.05
| | | Non-inflammatory change (%) | Mid (12) | Percent change: −30 | .02 | Percent change: −17 | NS | 0.05
| | | Total lesions change (%) | Mid (12) | Percent change: −31 | .02 | Percent change: −22 | .05 | NS
304 ↑ N=30 Cross-over Mild | | D.01.04 | Comedones change [phase i] (%) Count location: Undefined. | Short (2) | Benzoyl peroxide Percent change: −20 | NS | Salicylic acid Percent change: −34 | .01 | NS
| | | Comedones change [phase ii] (%) | Short (2) | Percent change: 10 | NS | Percent change: −9 | .05 | NS
272 Parallel | N=189 | D.01.05 | Total lesions change (%) Count location: Left side. | Long (14) | Benzoyl peroxide Percent change: −32 | | Sulfur + resorcinol Percent change: −16
243 ↑ Parallel | N=50 Mild/mod | D.01.09 | Total lesions change (%) | Short (6) | Benzoyl peroxide (2.5%) Percent change: −45 | | Benzoyl peroxide (10%) Percent change: −39 | | NS
| | | Total lesions change (%) | Mid (8) | Percent change: −47 | | Percent change: −45 | | NS
242 ↑ Parallel | N=52 Mild/mod | D.01.09 | Total lesions change (%) | Short (6) | Benzoyl peroxide (2.5%) Percent change: −54 | | Benzoyl peroxide (5%) Percent change: −47 | | NS
242 ↑ Parallel | N=52 Mild/mod | | Total lesions change (%) | Mid (8) | Percent change: −56 | | Percent change: −58 | | NS
221 ↓ Parallel | N=147 Mod | D.01.09 | Comedones change (%) | Mid (8) | Benzoyl peroxide (acetone) Percent change: −62 | | Benzoyl peroxide (alcohol) Percent change: −57 | | NS
| | | Papules change (%) | Mid (8) | Percent change: −56 | | Percent change: −56 | | 0.02
| | | Pustules change (%) | Mid (8) | Percent change: −80 | | Percent change: −79 | | NS
76 Parallel | N=48 Mod | D.01.09 | Inflammatory (count) Count location: Face (unspecified). Baseline counts: 32 (Target)/28 (Comparator) | Short (4) | Benzoyl peroxide (lotion) Percent Change*: −22 | .02 | Benzoyl peroxide (gel) Percent Change*: −32 | .01 | NS*
| | | Non-inflammatory (count) Count location: Face (unspecified). Baseline counts: 57 (Target)/58 (Comparator) | Short (4) | Percent Change*: −32 | .01 | Percent Change*: −17 | .01 | NS*
| | | Overall change/patient (% improvement) Count location: Vas. | Short (4) | Measure: 19 (4.) | | Measure: 22 (8.) | | NS*
| | | Severity (pillsbury) Count location: Face (unspecified). | Short (4) | Measure: 2 (1.1) | .05 | Measure: 2 (1.1) | .05 | NS*
| | | Inflammatory (count) Count location: Face (unspecified). Baseline counts: 32 (Target)/28 (Comparator) | Mid (8) | Percent Change*: −28 | .01 | Percent Change*: −39 | | NS*
| | | Non-inflammatory (count) Count location: Face (unspecified). Baseline counts: 57 (Target)/58 (Comparator) | Mid (8) | Percent Change*: −39 | .001 | Percent Change*: −28 | .001 | NS*
| | | Overall change/patient (% improvement) Count location: Vas. | Mid (8) | Measure: 28 (10.) | | Measure: 32 (20.) | | NS*
| | | Severity (pillsbury) Count location: Face (unspecified). | Mid (8) | Measure: 2 (0.5) | .01 | Measure: 2 (0.5) | .01 | NS*
118 Parallel | N=49 split face | D.01.09 | Closed comedones change (%) | Short (4) | Benzoyl peroxide (water) Percent change: −77 | | Benzoyl peroxide (alcohol) Percent change: −76 | | NS
| | | Cysts change (%) | Short (4) | Percent change: −100 | | Percent change: −100 | | NS
118 Parallel | N=49 split face | | Open comedones change (%) | Short (4) | Percent change: −95 | | Percent change: −100 | | NS
| | | Papules change (%) | Short (4) | Percent change: −70 | | Percent change: −73 | | NS
| | | Pustules change (%) | Short (4) | Percent change: −92 | | Percent change: −100 | | NS
| | | Closed comedones change (%) | Mid (8) | Percent change: −88 | | Percent change: −90 | | NS
| | | Cysts change (%) | Mid (8) | Percent change: −100 | | Percent change: −100 | | NS
| | | Open comedones change (%) | Mid (8) | Percent change: −100 | | Percent change: −100 | | NS
| | | Papules change (%) | Mid (8) | Percent change: −80 | | Percent change: −82 | | NS
| | | Pustules change (%) | Mid (8) | Percent change: −100 | | Percent change: −100 | | NS
D.05.01 | | | | Benzoyl peroxide + erythromycin | | | Placebo
310 ↑ Parallel | N=92 Mild/mod | | Comedones (count) Baseline counts: 7 (Target)/6 (Comparator) | Short (4) | Percent Change*: −50 | .004 | Percent Change*: −18 | .001 | NS
| | | Inflammatory (count) Baseline counts: 21 (Target)/18 (Comparator) | Short (4) | Percent Change*: −43 | .001 | Percent Change*: −19 | .003 | 0.008
| | | Total lesions (count) Baseline counts: 28 (Target)/29 (Comparator) | Short (4) | Percent Change*: −44 | .001 | Percent Change*: −31 | .001 | NS
| | | Comedones (count) Baseline counts: 7 (Target)/6 (Comparator) | Mid (12) | Percent Change*: −46 | .06 | Percent Change*: 00 | .001 | NS
| | | Inflammatory (count) Baseline counts: 21 (Target)/18 (Comparator) | Mid (12) | Percent Change*: −53 | .001 | Percent Change*: −26 | .02 | 0.01
| | | Total lesions (count) Baseline counts: 28 (Target)/29 (Comparator) | Mid (12) | Percent Change*: −51 | .001 | Percent Change*: −32 | .001 | NS
260 ↑ Parallel | N=205 Mild/mod | D.05.02 | Comedones (count) Count location: Face. | Short (4) | Erythromycin + benzoyl peroxide Raw count: 17 (42.) | | Clindamycin phosphate Raw count: 26 (42.) | | 0.001
| | | Inflammatory (count) | Short (4) | Raw count: 12 (7.) | | Raw count: 13 (7.) | | NS*
| | | Comedones (count) | Mid (10) | Raw count: 14 (42.) | | Raw count: 24 (42.) | | 0.001
260 ↑ Parallel | N=205 Mild/mod | | Inflammatory (count) Count location: Face. | Mid (10) | Raw count: 9 (29.) | | Raw count: 16 (29.) | | 0.001
| | | Overall change (score) | Mid (10) | Measure: 2 (1.7) | | Measure: 2 (1.7) | | NS*
| | | Overall change (score) | Mid (10) | Measure: 3 (3.8) | | Measure: 2 (3.8) | | NS*
62 ↓ Parallel | N=72 Mod | D.05.04 | Clinical assessment/physician (score) | Short (6) | Benzoyl peroxide + erythromycin Measure: 4 (0.9) | | Zinc + erythromycin Measure: 3 (1.1) | | 0.001
| | | Comedones change (median %) | Short (6) | Measure: −76 | | Measure: −48 | | NS
| | | Inflammatory change (count/median) | Short (6) | Measure: −35 | | Measure: −18 | | 0.005
| | | Clinical assessment/physician (score) | Mid (10) | Measure: 4 (0.7) | | Measure: 3 (1.1) | | 0.001
| | | Comedones change (median %) | Mid (10) | Measure: −87 | | Measure: −60 | | NS
| | | Inflammatory change (count/median) | Mid (10) | Measure: −53 | | Measure: −27 | | 0.005
30 ↑ Parallel | N=102 Mod | D.06.01 | Comedones (count) Count location: Face. Baseline counts: 9 (Target)/10 (Comparator) | Short (6) | Meclocycline + benzoyl peroxide Percent Change*: −11 | | Benzoyl peroxide Percent Change*: −58
| | | Papules (count) Count location: Face. Baseline counts: 21 (Target)/21 (Comparator) | Short (6) | Percent Change*: −38 | | Percent Change*: −48
| | | Pustules (count) Count location: Face. Baseline counts: 7 (Target)/9 (Comparator) | Short (6) | Percent Change*: −17 | | Percent Change*: −56
| | | Comedones (count) Count location: Face. Baseline counts: 9 (Target)/10 (Comparator) | Mid (10) | Percent Change*: −44 | | Percent Change*: −68 | | 0.05
| | | Papules (count) Count location: Face. Baseline counts: 21 (Target)/21 (Comparator) | Mid (10) | Percent Change*: −43 | | Percent Change*: −62 | | NS
| | | Pustules (count) Count location: Face. Baseline counts: 7 (Target)/9 (Comparator) | Mid (10) | Percent Change*: −23 | | Percent Change*: −58 | | NS
D.08.01 | | | | Benzoyl peroxide + miconazole | | | Benzoyl peroxide
111 ↓ Parallel | N=52 Mod/sev | | Comedones (count) Baseline counts: 61 (Target)/53 (Comparator) | Short (4) | Percent Change*: −41 | sig | Percent Change*: −49 | sig | NS
| | | Irritation | Short (4) | Measure: 0 (0.5) | | Measure: 1 (0.43) | | 0.01
| | | Irritation [Females] | Short (4) | Measure: 0 (0.42) | | Measure: 1 (0.28) | | 0.001
| | | Irritation [Male] | Short (4) | Measure: 0 (0.57) | | Measure: 1 (0.5) | | NS
| | | Papules (count) Baseline counts: 10 (Target)/8 (Comparator) | Short (4) | Percent Change*: −51 | sig | Percent Change*: −63 | sig | NS
| | | Pustules (count) Baseline counts: 4 (Target)/4 (Comparator) | Short (4) | Percent Change*: −65 | sig | Percent Change*: −79 | sig | NS
| | | Total lesions (count) Baseline counts: 73 (Target)/63 (Comparator) | Short (4) | Percent Change*: −44 | sig | Percent Change*: −52 | sig | NS
231 ↑ Parallel | N=20 Mild/mod/sev | | Comedones change (geometric mean) Count location: Face. | Mid (8) | Measure: −62 (28.) | | Measure: −54 (63.) | | NS
| | | Inflammatory change (geometric mean) | Mid (8) | Measure: −79 (15.) | | Measure: −98 (60.) | | NS
111 ↓ Parallel | N=52 Mod/sev | | Comedones (count) Baseline counts: 61 (Target)/53 (Comparator) | Mid (12) | Percent Change*: −65 | sig | Percent Change*: −72 | sig | NS
| | | Irritation | Mid (12) | Measure: 0 (0.32) | | Measure: 0 (0.46) | | NS
| | | Irritation [Female] | Mid (12) | Measure: 0 (0.28) | | Measure: 0 (0.49) | | NS
| | | Irritation [Male] | Mid (12) | Measure: 0 (0.34) | | Measure: 0 (0.42) | | NS
| | | Papules (count) Baseline counts: 10 (Target)/8 (Comparator) | Mid (12) | Percent Change*: −69 | sig | Percent Change*: −69 | sig | NS
| | | Pustules (count) Baseline counts: 4 (Target)/4 (Comparator) | Mid (12) | Percent Change*: −81 | sig | Percent Change*: −84 | sig | NS
| | | Total lesions (count) Baseline counts: 73 (Target)/63 (Comparator) | Mid (12) | Percent Change*: −66 | sig | Percent Change*: −73 | sig | NS
| | | Total lesions change (%) | Mid (12) | Percent change: −63 (27.1) | sig | Percent change: −69 (18.7) | sig | NS
111 ↓ Parallel | N=52 Mod/sev | | Total lesions change [female] (%) Between P-value: vs men. | Mid (12) | Percent change: −74 (15.9) | | Percent change: −73 (13.9) | | 0.02
| | | Total lesions change [male] (%) Between P-value: vs women. | Mid (12) | Percent change: −50 (30.7) | | Percent change: −66 (21.7) | | 0.02
85 ↑ Parallel | N=105 Mod | D.08.01 | Comedones (count) Count location: Entire face. Baseline counts: 36 (Target)/36 (Comparator) | Mid (8) | Miconazole + benzoyl peroxide Percent Change*: −75 | | Benzoyl peroxide Percent Change*: −61 | | 0.001
| | | Comedones (count) | Mid (12) | Percent Change*: −92 | | Percent Change*: −69 | | 0.001

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., - our assessment of entry severity of study patients. “P”- parallel study, “S”- split face design. TARGET and COMPARATOR: “Percent change”- an outcome derived from individual final and baseline measures; “Percent change*”- we calculated a group-based percentage change; “Change” - raw difference from baseline; “Change*” - calculated change; “Measure” - an outcome measure with no baseline comparison. SD: standard deviation. WITHIN P: P-value with respect to baseline in one arm. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table D3: DISCRETE outcomes for class ANTI-BACTERIAL (TOPICAL)/KERATOLYTIC (TOPICAL)

Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Treatment | Comparator | Between P-value
Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Attribute: Number of patients | Attribute: Number of patients | Between P-value
173 ↑ Parallel Mild/mod N=77 | D.01.01 | Local reactions I | Mid (12) | Benzoyl peroxide Scaling 7 Stinging 1 Itching 3 Peeling 2 | Vehicle Scaling 3 Stinging 2 Itching 0 Peeling 3
| | Local reactions II | Mid (12) | Erythema 10 Burning 3 soreness 3 Dryness 5 Roughness 1 | Erythema 1 Burning 0 soreness 0 Dryness 0 Roughness 1
176 ↓ Parallel Mild/mod N=150 | | Local effects | | Dryness, scaling, burning, stinging, redness 22 None 22 | Dryness, scaling, burning, stinging, redness 5 None 41 | 0.05
176 ↓ Parallel Mild/mod N=150 | D.01.03 | Local effects | | Benzoyl peroxide Dryness, scaling, burning, stinging, redness 22 None 22 | Gluconolactone Dryness, scaling, burning, stinging, redness 11 None 34 | 0.05
221 ↓ Parallel Mild/mod N=147 | D.01.09 | Severity change | Mid (8) | Benzoyl peroxide (acetone) Excellent 20 Good 15 Fair 11 Poor 8 | Benzoyl peroxide (alcohol) Excellent 11 Good 8 Fair 11 Poor 8 | NS
310 ↑ Parallel Mild/mod N=92 | D.05.01 | Side effects | Short (4) | Benzoyl peroxide + erythromycin Scaling or tightness 14 | Placebo Scaling or tightness 3 | NS
| | Side effects Between P-value: For scaling and burning | Mid (12) | Scaling or tightness 13 | Scaling or tightness 1 | 0.05
260 ↑ Parallel Mild/mod N=205 | D.05.02 | Side effects | Mid (10) | Erythromycin + benzoyl peroxide Mild - moderate 3 Withdraw 3 | Clindamycin phosphate Mild - moderate 1 Withdraw 0
62 ↓ Parallel Mode N=72 | D.05.04 | Improved by 50% or more | Short (6) | Benzoyl peroxide + erythromycin Improved by 50% or more 22 | Zinc + erythromycin Improved by 50% or more 8
| | Adverse effects | Mid (10) | Dryness/ irritation 1 | Dryness/ irritation 4
| | Improved by 50% or more | Mid (10) | Improved by 50% or more 30 | Improved by 50% or more 15
30 ↓ Parallel Mod N=102 | D.06.01 | Skin discoloration | Mid (10) | Meclocycline + benzoyl peroxide Present 1 Absent 32 | Benzoyl peroxide Present 1 Absent 35
121 ↑ Parallel Mod/sev N=43 | D.07.01 | Overall change/patient | Short (6) | Benzoyl peroxide + metronidazole Much worse 0 Worse 0 Unchanged 1 Somewhat improved 3 | Vehicle Much worse 0 Worse 0 Unchanged 11 Somewhat improved 1 | 0.05
| | Overall change/patient | Short (6) | Improved 4 Much improved 15 0-25% 3 26-50% 2 51-75% 6 76-100% 12 | Improved 6 Much improved 2 0-25% 9 26-50% 3 51-75% 8 76-100% 0 | 0.05
| | Severity change/photo | Short (6) | 0-25% 2 26-50% 5 51-75% 5 76-100% 11 | 0-25% 10 26-50% 4 51-75% 6 76-100% 0 | 0.05
122 ↑ Parallel Mod/sev N=60 | D.07.02 | Overall change/patient | Short (6) | Benzoyl peroxide + metronidazole Much worse 0 Worse 0 Unchanged 4 Somewhat improved 1 | Benzoyl peroxide Much worse 0 Worse 0 Unchanged 8 Somewhat improved 4 | 0.05
| | Overall change/physician | Short (6) | Improved 7 Much improved 18 0-25% 2 26-50% 2 51-75% 8 76-100% 18 | Improved 4 Much improved 13 0-25% 9 26-50% 3 51-75% 3 76-100% 14 | 0.05
| | Severity change/photo | Short (6) | 0-25% 3 26-50% 4 51-75% 4 76-100% 19 | 0-25% 8 26-50% 2 51-75% 3 76-100% 16 | 0.05
231 ↑ Parallel Mod/sev N=20 | D.08.01 | Overall assessment/patient | Mid (8) | Benzoyl peroxide + miconazole Excellent 7 Good 5 Moderate 1 None 1 | Benzoyl peroxide Excellent 5 Good 6 Moderate 2 None 3
| | Overall assessment/physician | Mid (8) | Excellent 7 Good 4 Moderate 2 None 1 | Excellent 7 Good 4 Moderate 2 None 3
| | Side effects | Mid (8) | Present 3 Absent 11 | Present 2 Absent 14 | NS
85 ↑ Parallel Mod N=105 | D.08.01 | Severity change (score shift) | Mid (8) | Miconazole + benzoyl peroxide −3 0 −2 0 −1 0 0 3 | Benzoyl peroxide −3 0 −2 0 −1 1 0 12 | 0.001
| | | | +1 26 +2 19 +3 1 | +1 28 +2 9 +3 0
85 ↑ Parallel Mod N=105 | | Overall change/patient | Mid (12) | Excellent 28 Good 17 Moderate 5 Bad 1 | Excellent 10 Good 17 Moderate 21 Bad 3 | 0.001
| | Overall change/physician | Mid (12) | Excellent 22 Good 21 Moderate 7 Bad 1 | Excellent 8 Good 13 Moderate 23 Bad 7 | 0.001
| | Severity change (score shift) | Mid (12) | −3 0 −2 0 −1 0 0 2 | −3 0 −2 0 −1 0 0 8 | 0.001
| | Side effects | Mid (12) | −1 15 −2 26 −3 4 Irritation/dryness 1 Allergic reaction 0 None 50 | −1 22 −2 16 −3 1 Irritation/dryness 10 Allergic reaction 1 None 40 | 0.005

TRIAL:↑↓ -presence of positive or negative methodological features (see Summary Table). “Mild/mod,” etc., -our assessment of entry severity of study patients. “P”- to parallel study, “S”-split face design. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table E1. Articles/arms for class RETINOID (TOPICAL)

Comp-Trial | | TARGET | | HEADING | | COMPARATOR | | Outcome Table(s)
Comp-Trial | | Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment | Outcome Table(s)
E.01.01 | 78 | Adapalene | 0.3 % topical qhs. | | Adapalene | 0.1 % topical qhs. | | Continuous
| 92 | Adapalene | 5 mg topical qd. | | Adapalene | 5 mg topical qd. | Waited 20-30 min after washing to apply gel. Cetaphil® gentle cleaning bar. | Continuous
| 338 | Adapalene | 0.03 % topical qhs. | Synthetic naphthoic acid derivative. | Adapalene | 0.1 % topical qhs. | Synthetic naphthoic acid derivative. | Continuous Discrete
E.01.02 | 49 | Adapalene | 0.1 % topical qhs. | To dry skin. | Tretinoin | 0.025 % topical qhs. | To dry skin. | Discrete
| 63 | Adapalene | 0.1 % topical qhs. | Normal washing and moisturizer, if required. | Tretinoin | 0.025 % topical qhs. | Normal washing and moisturizer, if required. | Discrete
| 78 | Adapalene | 0.1 % topical qhs. | | Tretinoin | 0.025 % topical qhs. | 1 hour before bedtime for 12 weeks. | Continuous
| | Adapalene | 0.3 % topical qhs. | | Tretinoin | 0.025 % topical qhs. | 1 hour before bedtime for 12 weeks. | Continuous
| 80 | Adapalene | 0.1 % topical qhs. | | Tretinoin | 0.025 % topical qhs. | | Continuous Discrete
| 93 | Adapalene | 0.1 % topical qd. | | Tretinoin | 0.025 % topical qd. | | Continuous Discrete
| 100 | Adapalene | 0.1 % topical qhs. | | Tretinoin | 0.025 % topical qhs. | | Continuous Discrete
| 119 | Adapalene | 0.1 % topical qd. | Under a nonporous adhesive bandage, applied to back at the same site each day (patch test). | Tretinoin | 0.1 % topical qd. | Same. | Continuous (M) Discrete
| 120 | Adapalene | 0.1 % topical qd. | Under a nonporous adhesive bandage, applied to back at the same site each day (patch test). | Tretinoin | 0.1 % topical qd. | Same. | Continuous (M) Discrete
| 140 | Adapalene | 0.1 % topical qhs. | Apply thin layer 15 min after washing and one hour before bed. | Tretinoin | 0.025 % topical qhs. | Apply thin layer 15 min after washing and one hour before bedtime; purchased commercially and relabeled. | Continuous Discrete
| 306 | Adapalene | 0.01 % topical qhs. | | Tretinoin | 0.025 % topical qhs. | | Continuous Discrete
E.01.02 | 338 | Adapalene | 0.1 % topical qhs. | Synthetic naphthoic acid derivative. | Tretinoin | 0.25 % topical qhs. | | Continuous Discrete
| | Adapalene | 0.03 % topical qhs. | Synthetic naphthoic acid derivative. | Tretinoin | 0.25 % topical qhs. | | Continuous Discrete
E.02.01 | 54 | Isotretinoin | 0.05 % topical bid. | | Vehicle | No dose information | | Continuous Discrete
| 173 | Isotretinoin | 0.05 % topical bid. | | Vehicle | No dose information | | Continuous Discrete
| 202 | Isotretinoin | 0.1 % topical bid. | | Vehicle | No dose information | | Continuous Discrete
| | Isotretinoin | 0.5 % topical bid. | | Vehicle | No dose information | | Continuous Discrete
E.02.02 | 173 | Isotretinoin | 0.05 % topical bid. | | Benzoyl peroxide | 5 % topical bid. | | Continuous Discrete
E.02.03 | 202 | Isotretinoin | 0.5 % topical bid. | | Isotretinoin | 0.1 % topical bid. | | Continuous Discrete
E.02.04 | 90 | Isotretinoin | 0.05 % topical qhs. | | Tretinoin | 0.05 % topical qhs. | | Continuous Discrete
| 98 | Isotretinoin | 0.05 % topical bid. | Began qhs and advanced to bid. Mild soap, avoid irritants, use sunblock. | Tretinoin | 0.05 % topical bid. | Began qhs and advanced to bid. Mild soap, avoid irritants, use sunblock. | Continuous Discrete
E.03.01 | 60 | Motretinide | 0.1 % topical bid. | | Vehicle | No dose information | | Discrete
| 61 | Motretinide | 0.1 % topical bid. | | Vehicle | No dose information | | Continuous Discrete
E.03.02 | 253 | Motretinide | 0.1 % topical bid. | | Motretinide | 0.1 % topical qd. | | Continuous Discrete
E.03.03 | 59 | Motretinide | 0.1 % topical bid. | | Tretinoin | 0.05 % topical bid. | | Continuous Discrete
| 60 | Motretinide | 0.1 % topical bid. | | Tretinoin | 0.05 % topical bid. | | Discrete
| 253 | Motretinide | 0.1 % topical bid. | | Tretinoin | 0.05 % topical qd. | | Continuous Discrete
| | Motretinide | 0.1 % topical qd. | | Tretinoin | 0.05 % topical qd. | | Continuous Discrete
E.04.01 | 145 | Retinyl beta-glucuronide | 1.2 % topical bid. | Water soluble endogenous metabolite of vitamin A. Pre-Sun® 29 sunscreen. | Vehicle | No dose information | Pre-Sun® 29 sunscreen. | Continuous Discrete
E.04.02 | 146 | Retinyl beta-glucuronide | 0.24 % topical qd. | 0.16% for 10 weeks, 0.24% for 12 weeks, then 0.32% for 4 weeks. Pre-Sun® 29 sunscreen. | Tretinoin | 0.1 % topical qd. | Pre-Sun® 29 sunscreen. | Continuous Discrete
E.05.01 | 58 | Tretinoin | 0.02 % topical bid. | Frequency varied if irritated. | Vehicle | No dose information | | Continuous Discrete
| | Tretinoin | 0.05 % topical bid. | | Vehicle | No dose information | | Continuous Discrete
| 60 | Tretinoin | 0.05 % topical bid. | | Vehicle | No dose information | | Discrete
| 119 | Tretinoin | 0.05 % topical qd. | Same. | Petrolatum | No dose information | Same. | Continuous (M) Discrete
| 120 | Tretinoin | 0.025 % topical qd. | Same. | Petrolatum | No dose information | Same. | Continuous (M) Discrete
| 198 | Tretinoin | 0.025 % topical qd. | Qd or bid x 6 weeks then reduced to alternate days as tolerated; 0.7cc per swab. | Vehicle | 0.7 cc topical qd. | Qd or bid then reduced to alternate days, as tolerated. | Continuous Discrete
| | Tretinoin | 0.05 % topical qd. | Qd or bid x 6 weeks then reduced to alternate days as tolerated; 0.7cc per swab. | Vehicle | 0.7 cc topical qd. | Qd or bid then reduced to alternate days, as tolerated. | Continuous Discrete
| 219 | Tretinoin | 0.025 % topical qhs. | 1/2 inch ribbon. Purpose® soap. | Polyoprepolymer-2 | 0.5 inch topical qhs. | Purpose® soap. | Continuous Discrete
| | Polyoprepolymer-2 Tretinoin | No dose information. 0.025 % topical qhs. | 1/2 inch ribbon. Purpose® soap. | Polyoprepolymer-2 | 0.5 inch topical qhs. | Purpose® soap. | Continuous Discrete
| 220 | Tretinoin | 0.025 % topical qhs. | Purpose® soap; Durascreen® sunscreen, if needed. | Vehicle | No dose information | Purpose® soap; Durascreen® sunscreen, if needed. | Continuous Discrete
| | Tretinoin | 0.025 % topical qhs. | Purpose® soap; Durascreen® sunscreen, if needed. | Vehicle | No dose information | Purpose® soap; Durascreen® sunscreen, if needed. | Continuous Discrete
E.05.01 | 270 | Tretinoin | 0.05 % topical bid. | | Vehicle | No dose information | | Discrete
E.05.015 | 84 | Tretinoin | 0.05 % topical qd. | Vehicle ethanol+alpha-toapherolq | Sulphur Resorcinol Salicylic acid | No dose information 3 % topical qd. 3 % topical qd. | | Discrete
E.05.02 | 38 | Tretinoin | 0.025 % topical bid. | | Benzoyl peroxide | 5 % topical bid. | | Continuous Discrete
| 149 | Tretinoin | 0.05 % topical bid. | Vehicle alcohol. | Benzoyl peroxide | 10 % topical bid. | | Continuous (M) Discrete
| 221 | Tretinoin | 0.1 % topical qd. | At least once a day then as needed; may be discontinued for few days it irritation. | Benzoyl peroxide | 5 % topical qd. | | Continuous Discrete
| | Tretinoin | 0.1 % topical qd. | At least once a day then as needed; may be discontinued for few days it irritation. | Benzoyl peroxide | 5 % topical qd. | 4 weeks 5%; 4 weeks 10%; once or twice/day. | Continuous Discrete
E.05.04 | 188 | Tretinoin | 0.05 % topical bid. | | Azelaic acid | 20 % topical bid. | Frequency was qd for first 2 weeks. | Continuous Discrete
| 316 | Vehicle Tretinoin | No dose information. 0.025 % topical qd. | | Glycolic acid Azelaic acid | 20 % topical qhs. 20 % topical bid. | Glycolic acid 15% for first month; glycolic acid at evening. | Continuous Discrete
E.05.07 | 58 | Tretinoin | 0.02 % topical bid. | Frequency varied if irritated. | Tretinoin | 0.05 % topical bid. | | Continuous Discrete
| 84 | Tretinoin | 0.05 % topical qd. | Vehicle ethanol+alpha-toapherolq | Sulphur Resorcinol Salicylic acid | No dose information 3 % topical qd. 3 % topical qd. | | Discrete
| 119 | Tretinoin | 0.025 % topical qd. | Same. | Tretinoin | 0.01 % topical qd. | Same. | Continuous (M) Discrete
| 120 | Tretinoin | 0.025 % topical qd. | Same. | Tretinoin | 0.1 % topical qd. | Same. | Continuous (M) Discrete
| 198 | Tretinoin | 0.025 % topical qd. | Qd or bid x 6 weeks then reduced to alternate days as tolerated; 0.7cc per swab. | Tretinoin | 0.05 % topical qd. | Qd or bid x 6 weeks then reduced to alternate days as tolerated; 0.7cc per swab. | Continuous Discrete
E.05.07 | 219 | Polyoprepolymer-2 Tretinoin | No dose information. 0.025 % topical qhs. | 1/2 inch ribbon. Purpose® soap. | Tretinoin | 0.025 % topical qhs. | 1/2 inch ribbon. Purpose® soap. | Continuous Discrete
| 220 | Tretinoin | 0.025 % topical qhs. | Purpose® soap; Durascreen® sunscreen, if needed. | Tretinoin | 0.025 % topical qhs. | Purpose® soap; Durascreen® sunscreen, if needed. | Continuous Discrete
| 302 | Tretinoin | 0.05 % topical qhs. | | Tretinoin | 0.025 % topical qhs. | Or tretinoin 0.05%; combined results for acne outcomes. | Continuous (M) Discrete
E.05.08 | 13 | Tretinoin | 0.025 % topical bid. | Frequency was qd for fair, sensitive skin or for erythema equivalent to a mild sunburn. | Neomycin Methylprednisolone | No dose information No dose information | Frequency was qd for fair, sensitive skin or for erythema equivalent to a mild sunburn. | Continuous Discrete
E.05.09 | 37 | Tretinoin | 0.025 % topical bid. | Mild soap. | Hydrocortisone Chloramphenicol | 10 % topical bid. 10 % topical bid. | Mild soap. | Continuous Discrete
E.06.01 | 34 | Vitamin A | 0.05 % topical bid. | | Vehicle | No dose information | | Discrete
| 35 | Vitamin A | 0.05 % topical bid. | | Vehicle | No dose information | | Continuous Discrete
E.06.02 | 272 | Vitamin A | 0.1 % topical (can't say) | | Resorcinol Sulphur | 3 % topical (can't say) 5 % topical (can't say) | | Continuous
E.06.03 | 57 | Vitamin A Placebo | 0.05 % topical qd. No dose information. | First week 2x1 day; 2-7 weeks 1x1 day. | Oxytetracycline Vehicle | 250 mg oral qd. No dose information. | | Discrete

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table E2. CONTINUOUS outcomes for class RETINOID (TOPICAL)

Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Target | | Comparator | | Between P-value
Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Data Type: Mean (SD) | Within P | Data Type: Mean (SD) | Within P | Between P-value
338 ↑ Parallel | N=72 Mild/mod/sev | E.01.01 | Inflammatory change (%) Count location: Face. | Short (4) | Adapalene (0.03%) Percent change: −8 | | Adapalene (0.1%) Percent change: −25
78 | N=89 | | Total lesions change (%) Count location: Face excluding nose. | Short (4) | Percent change: −30 | | Percent change: −45
338 | N=72 | | Inflammatory change (%) Count location: Face. | Mid (12) | Percent change: −45 | | Percent change: −65 | NS | 0.05
| | | Non-inflammatory (count) | Mid (12) | Raw count: 28 (22.5) | | Raw count: 20 (26.9) | NS | 0.05
| | | Severity (leeds) | Mid (12) | Measure: 1 (0.49) | | Measure: 0 (0.25) | | 0.05
78 | N=89 | | Total lesions change (%) Count location: Face excluding nose. | Mid (12) | Percent change: −53 | | Percent change: −72
92 ↓ N=25 Parallel split face Mild/mod | | E.01.01 | Dryness (score) | Short (2) | Adapalene-delayed Measure: 1 | | Adapalene-immediate Measure: 1 | | NS
| | | Erythema (score) | Short (2) | Measure: 1 | | Measure: 1 | | NS
93 ↑ N=100 Parallel split face Mild/mod | | E.01.02 | Desquamation | Short (0) | Adapalene Measure: 0 (0.24) | | Tretinoin Measure: 0 (0.2) | | 1
| | | Dryness (score) | Short (0) | Measure: 0 (0.3) | | Measure: 0 (0.31) | | 1
| | | Erythema (score) | Short (0) | Measure: 1 (0.52) | | Measure: 1 (0.52) | | NS
| | | Stinging/burning | Short (0) | Measure: 0 (0.) | | Measure: 0 (0.) | | 1
| | | Total adverse skin symptom (score) | Short (0) | Measure: 1 (0.7) | | Measure: 1 (0.68) | | NS
| | | Desquamation | Short (4) | Measure: 0 (0.71) | | Measure: 1 (0.87) | | 0.034
| | | Erythema (score) | Short (4) | Measure: 2 (0.87) | | Measure: 2 (0.52) | | 0.021
100 Parallel | N=297 Mod | | Inflammatory (count) Count location: Entire face. Baseline counts: 26 (Target)/26 (Comparator) | Short (4) | Percent Change*: −23 | | Percent Change*: −19 | | NS
80 ↑ Parallel | N=268 | | Inflammatory change (%) Count location: Face excluding nose. | Short (4) | Percent change: −39 | | Percent change: −35
140 ↑ Parallel | N=105 Mild/mod | | Inflammatory change (%) | Short (4) | Percent change: −45 | | Percent change: −35 | | NS
93 N=100 Parallel split face Mild/mod | | | Local reactions/Dryness (score) | Short (4) | Measure: 1 (0.78) | | Measure: 1 (0.89) | | 0.017
100 Parallel | N=297 Mod | | Non-inflammatory (count) Count location: Entire face. Baseline counts: 50 (Target)/52 (Comparator) | Short (4) | Percent Change*: −28 | | Percent Change*: −25 | | NS
80 ↑ Parallel | N=268 | | Non-inflammatory change (%) Count location: Face excluding nose. | Short (4) | Percent change: −30 | | Percent change: −16
140 ↑ Parallel | N=105 Mild/mod | | Non-inflammatory change (%) | Short (4) | Percent change: −41 | | Percent change: −42 | | NS
| | | Severity (leeds) [per protocol] | Short (4) | Measure: 1 (0.7) | | Measure: 1 (0.7) | | NS
| | | Severity change (leeds %) [per protocol] | Short (4) | Measure: −42 (36.4) | | Measure: −34 (36.7) | | NS
93 N=100 Parallel split face Mild/mod | | | Stinging/burning | Short (4) | Measure: 0 (0.82) | | Measure: 1 (0.85) | | NS
| | | Total adverse skin symptoms (score) | Short (4) | Measure: 4 (2.33) | | Measure: 5 (2.64) | | 0.011
306 ↑ Parallel | N=288 Mod | | % Burning grade I | Mid (12) | Measure: 3 | | Measure: 8 | | NS
| | | % Dryness grade I | Mid (12) | Measure: 36 | | Measure: 48 | | 0.05
| | | % Erythema grade I | Mid (12) | Measure: 35 | | Measure: 45 | | 0.05
| | | % Scaling grade | Mid (12) | Measure: 22 | | Measure: 42 | | 0.05
100 ↑ | N=297 | | Inflammatory (count) Count location: Entire face. Baseline counts: 26 (Target)/26 (Comparator) | Mid (12) | Percent Change*: −42 | | Percent Change*: −46 | | NS
| | | Inflammatory change (%) Count location: Entire face. | Mid (12) | Percent change: −47 | | Percent change: −50 | | NS
140 Parallel | N=105 Mild/mod | | Inflammatory change (%) | Mid (12) | Percent change: −58 | | Percent change: −61 | | NS
80 ↑ Parallel | N=268 | | Inflammatory change (%) Count location: Face excluding nose. | Mid (12) | Percent change: −65 | | Percent change: −65
306 Parallel | N=288 Mod | | Inflammatory change (%) | Mid (12) | Percent change: −48 | | Percent change: −38 | | 0.01
100 ↑ | N=297 | | Non-inflammatory (count) Count location: Entire face. Baseline counts: 50 (Target)/52 (Comparator) | Mid (12) | Percent Change*: −56 | | Percent Change*: −52 | | NS
306 ↑ | N=288 | | Non-inflammatory change (%) | Mid (12) | Percent change: −46 | | Percent change: −33 | | 0.05
80 Parallel | N=268 | | Non-inflammatory change (%) Count location: Face excluding nose. | Mid (12) | Percent change: −55 | | Percent change: −60
100 ↑ Parallel | N=297 Mod | | Non-inflammatory change (%) Count location: Entire face. | Mid (12) | Percent change: −57 | | Percent change: −54 | | NS
140 Parallel | N=105 Mild/mod | | Non-inflammatory change (%) | Mid (12) | Percent change: −50 | | Percent change: −61 | | NS
100 Parallel | N=297 Mod | | Severity (leeds) Count location: Entire face. | Mid (12) | Measure: 1 | .001 | Measure: 1 | .001 | NS
140 Parallel | N=105 Mild/mod | | Severity (leeds) [intention to treat] | Mid (12) | Measure: 1 (0.6) | | Measure: 1 (0.6) | | NS
| | | Severity (leeds) [per protocol] | Mid (12) | Measure: 1 (0.6) | | Measure: 1 (0.4) | | NS
| | | Severity change (leeds %) [intention to treat] | Mid (12) | Measure: −51 (36.6) | | Measure: −62 (31.3) | | NS
| | | Severity change (leeds %) [per protocol] | Mid (12) | Measure: −56 (36.1) | | Measure: −72 (21.2) | | NS
100 Parallel | N=297 Mod | | Total lesions change (%) Count location: Entire face. | Mid (12) | Percent change: −54 | | Percent change: −52 | | NS
306 ↑ | N=288 | | Total lesions change (%) | Mid (12) | Percent change: −49 | | Percent change: −37 | | 0.01
338 ↑ Parallel | N=72 Mild/mod/sev | E.01.02 | Inflammatory change (%) Count location: Face. | Short (4) | Adapalene (0.03%) Percent change: −8 | | Tretinoin Percent change: 3
78 | N=89 | | Total lesions change (%) Count location: Face excluding nose. | Short (4) | Percent change: −30 | | Percent change: −50
338 | N=72 | | Inflammatory change (%) Count location: Face. | Mid (12) | Percent change: −45 | | Percent change: −42 | | 0.05
338 ↑ Parallel | N=72 Mild/mod/sev | | Non-inflammatory (count) Count location: Face. | Mid (12) | Raw count: 28 (22.5) | | Raw count: 17 (10.8) | NS | 0.05
| | | Severity (leeds) | Mid (12) | Measure: 1 (0.49) | | Measure: 1 (0.83) | | 0.05
78 | N=89 | | Total lesions change (%) Count location: Face excluding nose. | Mid (12) | Percent change: −53 | | Percent change: −78
338 ↑ Parallel | N=72 Mild/mod/sev | E.01.02 | Inflammatory change (%) Count location: Face. | Short (4) | Adapalene (0.1%) Percent change: −25 | | Tretinoin Percent change: 3
78 | N=89 | | Total lesions change (%) Count location: Face excluding nose. | Short (4) | Percent change: −45 | | Percent change: −50
| | | Inflammatory (count) Baseline counts: 35 (Target)/41 (Comparator) | Mid (12) | Percent Change*: −69 | | Percent Change*: −73
338 | N=72 | | Inflammatory change (%) Count location: Face. | Mid (12) | Percent change: −65 | NS | Percent change: −42 | | 0.05
| | | Non-inflammatory (count) | Mid (12) | Raw count: 20 (26.9) | NS | Raw count: 17 (10.8) | NS | NS*
78 | N=89 | | Non-inflammatory (count) Count location: Face excluding nose. Baseline counts: 60 (Target)/88 (Comparator) | Mid (12) | Percent Change*: −77 | | Percent Change*: −81
338 | N=72 | | Severity (leeds) Count location: Face. | Mid (12) | Measure: 0 (0.25) | | Measure: 1 (0.83) | | NS
78 | N=89 | | Severity (leeds) Count location: Face excluding nose. | Mid (12) | Measure: 0 | | Measure: 1 | | 0.01
| | | Total lesions change (%) | Mid (12) | Percent change: −72 | | Percent change: −78
173 ↑ Parallel | N=77 Mild/mod | E.02.01 | Inflammatory (count) Count location: Face. Baseline counts: 40 (Target)/44 (Comparator) | Short (4) | Isotretinoin Percent Change*: −05 | NS | Vehicle Percent Change*: −05 | NS | “significant”
| | | Non-inflammatory (count) Count location: Face. Baseline counts: 45 (Target)/49 (Comparator) | Short (4) | Percent Change*: −16 | .05 | Percent Change*: 02
173 ↑ Parallel | N=77 Mild/mod | | Severity (leeds) Count location: Face. | Short (4) | Measure: 1 | NS | Measure: 1 | NS | NS
54 Parallel | N=313 | | Inflammatory change (%) Between P-value: no P value given. | Short (5) | Percent change: −25 | | Percent change: −15 | | “significant”
| | | Non-inflammatory change (%) | Short (5) | Percent change: −26 | | Percent change: −17 | | NS
| | | Severity change (cook %) | Short (5) | Measure: −18 | | Measure: −11 | | NS
| | | Inflammatory change (%) Between P-value: no P value given. | Mid (11) | Percent change: −50 | | Percent change: −23 | | “significant”
| | | Non-inflammatory change (%) | Mid (11) | Percent change: −36 | | Percent change: −13 | | “significant”
| | | Severity change (cook %) | Mid (11) | Measure: −33 | | Measure: −18 | | “significant”
173 Parallel | N=77 Mild/mod | | Inflammatory (count) Count location: Face. Baseline counts: 40 (Target)/44 (Comparator) | Mid (12) | Percent Change*: −33 | .01 | Percent Change*: 09 | NS | 0.01
| | | Non-inflammatory (count) Count location: Face. Baseline counts: 45 (Target)/49 (Comparator) | Mid (12) | Percent Change*: −47 | .01 | Percent Change*: 06 | NS | 0.01
| | | Severity (leeds) Count location: Face. | Mid (12) | Measure: 0 | .01 | Measure: 1 | | 0.05
54 Parallel | N=313 | | Inflammatory change (%) Between P-value: no P value given. | Long (14) | Percent change: −55 | | Percent change: −25 | | “significant”
| | | Non-inflammatory change (%) | Long (14) | Percent change: −46 | | Percent change: −14 | | “significant”
| | | Severity change (cook %) | Long (14) | Measure: −40 | | Measure: −20 | | “significant”
202 Parallel | N=82 Mild/mod | E.02.01 | Closed comedones (count) Count location: Face. Baseline counts: 23 (Target)/18 (Comparator) | Short (4) | Isotretinoin (0.05%) Percent Change*: −19 | NS | Vehicle Percent Change*: 11 | NS | NS*
| | | Papules (count) Count location: Face. Baseline counts: 23 (Target)/20 (Comparator) | Short (4) | Percent Change*: −26 | .01 | Percent Change*: −30 | .01 | NS*
202 Parallel | N=82 Mild/mod | | Closed comedones (count) Count location: Face. Baseline counts: 23 (Target)/18 (Comparator) | Mid (12) | Percent Change*: −47 | .01 | Percent Change*: −14 | NS | NS*
| | | Papules (count) Count location: Face. Baseline counts: 23 (Target)/20 (Comparator) | Mid (12) | Percent Change*: −34 | .001 | Percent Change*: −49 | .01 | NS*
202 Parallel | N=82 Mild/mod | E.02.01 | Closed comedones (count) Count location: Face. Baseline counts: 21 (Target)/18 (Comparator) | Short (4) | Isotretinoin (0.1%) Percent Change*: −20 | NS | Vehicle Percent Change*: 11 | NS | NS*
| | | Papules (count) Count location: Face. Baseline counts: 23 (Target)/20 (Comparator) | Short (4) | Percent Change*: −32 | .01 | Percent Change*: −30 | .01 | NS*
| | | Closed comedones (count) Count location: Face. Baseline counts: 21 (Target)/18 (Comparator) | Mid (12) | Percent Change*: −46 | .01 | Percent Change*: −14 | NS | NS*
| | | Papules (count) Count location: Face. Baseline counts: 23 (Target)/20 (Comparator) | Mid (12) | Percent Change*: −60 | .01 | Percent Change*: −49 | .01 | NS*
173 ↑ Parallel | N=77 Mild/mod | E.02.02 | Inflammatory (count) Count location: Face. Baseline counts: 40 (Target)/44 (Comparator) | Short (4) | Isotretinoin Percent Change*: −05 | NS | Benzoyl peroxide Percent Change*: −43 | | “significant”
| | | Non-inflammatory (count) Count location: Face. Baseline counts: 45 (Target)/48 (Comparator) | Short (4) | Percent Change*: −16 | .05 | Percent Change*: −23 | .05
| | | Severity (leeds) Count location: Face. | Short (4) | Measure: 1 | NS | Measure: 1 | .01 | NS
| | | Inflammatory (count) Count location: Face. Baseline counts: 40 (Target)/44 (Comparator) | Mid (12) | Percent Change*: −33 | .01 | Percent Change*: −52 | .01 | 0.01
173 ↑ Parallel | N=77 Mild/mod | | Non-inflammatory (count) Count location: Face. Baseline counts: 45 (Target)/48 (Comparator) | Mid (12) | Percent Change*: −47 | .01 | Percent Change*: −52 | .01 | 0.01
| | | Severity (leeds) Count location: Face. | Mid (12) | Measure: 0 | .01 | Measure: 0 | .01 | 0.05
202 Parallel | N=82 Mild/mod | E.02.03 | Closed comedones (count) Count location: Face. Baseline counts: 23 (Target)/21 (Comparator) | Short (4) | Isotretinoin (0.05%) Percent Change*: −19 | NS | Isotretinoin (0.1%) Percent Change*: −20 | NS | NS*
| | | Papules (count) Count location: Face. Baseline counts: 23 (Target)/23 (Comparator) | Short (4) | Percent Change*: −26 | .01 | Percent Change*: −32 | .01 | NS*
| | | Closed comedones (count) Count location: Face. Baseline counts: 23 (Target)/21 (Comparator) | Mid (12) | Percent Change*: −47 | .01 | Percent Change*: −46 | .01 | NS*
| | | Papules (count) Count location: Face. Baseline counts: 23 (Target)/23 (Comparator) | Mid (12) | Percent Change*: −34 | .001 | Percent Change*: −60 | .01 | NS*
90 ↑ Parallel | N=30 Mod | E.02.04 | Comedones (count) Baseline counts: 40 (Target)/33 (Comparator) | Short (4) | Isotretinoin Percent Change*: −50 | | Tretinoin Percent Change*: −39
| | | Inflammatory (count) Baseline counts: 13 (Target)/13 (Comparator) | Short (4) | Percent Change*: −54 | | Percent Change*: −62
| | | Comedones (count) Baseline counts: 40 (Target)/33 (Comparator) | Mid (12) | Percent Change*: −78 | | Percent Change*: −70
98 Parallel | N=18 | | Comedones change (%) | Mid (12) | Percent change: −37 (49.) | sig | Percent change: −32 (55.) | sig | NS
90 ↑ Parallel | N=30 Mod | | Inflammatory (count) Baseline counts: 13 (Target)/13 (Comparator) | Mid (12) | Percent Change*: −77 | | Percent Change*: −77
98 Parallel | N=18 | | Inflammatory change (%) | Mid (12) | Percent change: −57 (25.) | .01 | Percent change: −46 (29.) | .01 | NS
| | | Total lesions change (%) | Mid (12) | Percent change: −51 (27.) | | Percent change: −47 (37.) | | NS
61 ↓ Parallel | N=19 | E.03.01 | Comedones change (count) Baseline counts: 9 (Target)/9 (Comparator) | Short (4) | Motretinide Percent change*: −33 | .05 | Vehicle Percent change*: −11 | NS | NS
| | | Total lesions change (count) Baseline counts: 12 (Target)/16 (Comparator) | Short (4) | Percent change*: −42 | .01 | Percent change*: −13 | NS | NS
| | | Comedones change (count) Baseline counts: 9 (Target)/9 (Comparator) | Mid (7) | Percent change*: −67 | .05 | Percent change*: −11 | NS | NS
| | | Total lesions change (count) Baseline counts: 12 (Target)/16 (Comparator) | Mid (7) | Percent change*: −75 | .01 | Percent change*: −23 | NS | NS
253 ↑ Parallel | N=60 Mod/sev | E.03.02 | Papules (count) Baseline counts: 9 (Target)/10 (Comparator) | Mid (8) | Motretinide (bid) Percent Change*: −56 | .005 | Motretinide (qd) Percent Change*: −50 | .01 | NS
| | | Pustules (count) Baseline counts: 11 (Target)/10 (Comparator) | Mid (8) | Percent Change*: −64 | .001 | Percent Change*: −70 | .01 | NS
59 ↑ Parallel | N=37 Mild | E.03.03 | Total lesions change (count/median) Count location: Worst area/5cm diameter. | Mid (8) | Motretinide Measure: −5 | .01 | Tretinoin Measure: −8 | .01 | NS
253 ↑ Parallel | N=60 Mod/sev | E.03.03 | Papules (count) Baseline counts: 9 (Target)/7 (Comparator) | Mid (8) | Motretinide (bid) Percent Change*: −56 | .005 | Tretinoin Percent Change*: −71 | .001 | NS
253 ↑ Parallel | N=60 Mod/sev | | Pustules (count) Baseline counts: 11 (Target)/10 (Comparator) | Mid (8) | Percent Change*: −64 | .001 | Percent Change*: −50 | .01 | NS
253 ↑ Parallel | N=60 Mod/sev | E.03.03 | Papules (count) Baseline counts: 10 (Target)/7 (Comparator) | Mid (8) | Motretinide (qd) Percent Change*: −50 | .01 | Tretinoin Percent Change*: −71 | .001 | NS
| | | Pustules (count) Baseline counts: 10 (Target)/10 (Comparator) | Mid (8) | Percent Change*: −70 | .01 | Percent Change*: −50 | .01 | NS
145 ↑ Parallel | N=29 Mild/mod | E.04.01 | Total lesions (ratio to initial) Count location: Side of face (spilt face trial). | Short (4) | Retinyl beta-glucuronide Measure: 1 | | Vehicle Measure: 1
| | | Total lesions change (ratio to initial) Count location: Side of face (split face trail). | Mid (12) | Measure: 1 | | Measure: 1
| | | Overall change/physician (score) Count location: Side of face (spilt face trial). | Long (16) | Measure: 3 | | Measure: 3
| | | Inflammatory (count/median) | Long (18) | Measure: 23 | .07 | Measure: 27 | NS
| | | Inflammatory change (ratio to initial) | Long (18) | Measure: 1 | | Measure: 1
| | | Non-inflammatory (count/median) | Long (18) | Measure: 10 | .001 | Measure: 11 | .01
| | | Non-inflammatory change (ratio to initial) | Long (18) | Measure: 0 | | Measure: 0
| | | Total lesions (count/median) | Long (18) | Measure: 28 | .002 | Measure: 41 | .06
| | | Total lesions change (ratio to intitial) | Long (18) | Measure: 0 | | Measure: 1
146 ↑ Parallel | N=15 Mild/mod | E.04.02 | Total lesions change (ratio to initial) Count location: Side of face. | Short (6) | Retinyl beta-glucuronide Measure: 1 | | Tretinoin Measure: 1
| | | Total lesions change (ratio to initial) | Mid (8) | Measure: 1 | | Measure: 1
| | | Inflammatory (count/median) | Long (28) | Measure: 3 | | Measure: 6
| | | Inflammatory lesion (ration to initial) | Long (28) | Measure: 0 | | Measure: 0
| | | Non-inflammatory (count/median) | Long (28) | Measure: 4 | | Measure: 6
| | | Non-inflammatory change (ratio to initial) | Long (28) | Measure: 0 | | Measure: 0
146 ↑ Parallel | N=15 Mild/mod | | Overall change/physician (score) Count location: Side of face. | Long (28) | Measure: 4 | .05 | Measure: 4 | .05
| | | Total lesions (count/median) | Long (28) | Measure: 7 | | Measure: 10 | | NS
| | | Total lesions change (ratio to initial) | Long (28) | Measure: 0 | | Measure: 0 | | 0.06
219 ↑ Parallel | N=344 Mild/mod | E.05.01 | Inflammatory change (%) | Short (4) | Tretinoin Percent change: −22 | | Polyoprepolymer-2 Percent change: −11
| | | Non-inflammatory change (%) | Short (4) | Percent change: −25 (21.) | | Percent change: −5 | | NS
| | | Total lesions change (%) | Short (4) | Percent change: −25 (21.) | | Percent change: −7
| | | Inflammatory change (%) | Mid (12) | Percent change: −48 (92.) | | Percent change: −32 (92.)
| | | Non-inflammatory change (%) | Mid (12) | Percent change: −48 (12.) | | Percent change: −28 | | NS
| | | Total lesions change (%) | Mid (12) | Percent change: −49 (12.) | | Percent change: −28 | | NS
58 ↓ Parallel | N=256 Sev | E.05.01 | Comedones severity (christiansen) Count location: Worst area. | Short (4) | Tretinoin (0.02%) Measure: 118 | | Vehicle Measure: 157 | | 0.05
| | | Nodes+cysts (score) | Short (4) | Measure: 10 | | Measure: 18 | | NS
| | | Papules severity (christiansen) | Short (4) | Measure: 85 | | Measure: 108 | | NS
| | | Pustules (score) | Short (4) | Measure: 64 | | Measure: 87 | | NS
| | | Comedones (christiansen) | Mid (8) | Measure: 94 | | Measure: 131 | | 0.01
| | | Nodes+cysts (score) | Mid (8) | Measure: 9 | | Measure: 14 | | NS
| | | Papules severity (christiansen) | Mid (8) | Measure: 76 | | Measure: 83 | | NS
| | | Pustules (score) | Mid (8) | Measure: 42 | | Measure: 67 | | NS
198 ↑ Parallel | N=60 | E.05.01 | Comedones (count) Count location: 2.5 cm. Baseline counts: 29 (Target)/20 (Comparator) | Mid (12) | Tretinoin (0.025%) Percent Change*: −62 | | Vehicle Percent Change*: 25
| | | Papules (count) Count location: 2.5 cm. Baseline counts: 10 (Target)/12 (Comparator) | Mid (12) | Percent Change*: −80 | | Percent Change*: 317
198 ↑ Parallel | N=60 | | Pustules (count) Count location: 2.5 cm. Baseline counts: 2 (Target)/2 (Comparator) | Mid (12) | Percent Change*: −87 | | Percent Change*: −65
| | | Severity/patient (vas) | Mid (12) | Measure: 20 | | Measure: 39
58 ↓ Parallel | N=256 Sev | E.05.01 | Comedones severity (christiansen) Count location: Worst area. | Short (4) | Tretinoin (0.05%) Measure: 120 | | Vehicle Measure: 157 | | 0.01
| | | Nodes+cysts (score) | Short (4) | Measure: 20 | | Measure: 18 | | NS
| | | Papules severity (christiansen) | Short (4) | Measure: 92 | | Measure: 108 | | 0.05
| | | Pustules (score) | Short (4) | Measure: 71 | | Measure: 87 | | NS
| | | Comedones (christiansen) | Mid (8) | Measure: 89 | | Measure: 131 | | 0.01
| | | Nodes+cysts (score) | Mid (8) | Measure: 15 | | Measure: 14 | | NS
| | | Papules severity (christiansen) | Mid (8) | Measure: 61 | | Measure: 83 | | 0.05
| | | Pustules (score) | Mid (8) | Measure: 35 | | Measure: 67 | | NS
198 ↑ Parallel | N=60 | | Comedones (count) Count location: 2.5 cm. Baseline counts: 18 (Target)/20 (Comparator) | Mid (12) | Percent Change*: −59 | | Percent Change*: 25
| | | Papules (count) Count location: 2.5 cm. Baseline counts: 8 (Target)/12 (Comparator) | Mid (12) | Percent Change*: −65 | | Percent Change*: 317
| | | Pustules (count) Count location: 2.5 cm. Baseline counts: 3 (Target)/2 (Comparator) | Mid (12) | Percent Change*: −85 | | Percent Change*: −65
| | | Severity/patient (vas) | Mid (12) | Measure: 18 | | Measure: 39
220 Parallel | N=215 Mild/mod | E.05.01 | Inflammatory change (%) Between P-value: vs vehicle. | Short (4) | Tretinoin (ethanol) Percent change: −41 | | Vehicle Percent change: −19 | | 0.05
| | | Inflammatory change (%) | Short (4) | Percent change: −25 | | Percent change: −18 | | NS
| | | Non-inflammatory change (%) | Short (4) | Percent change: −21 | | Percent change: −12 | | NS
| | | Total lesions change (%) | Short (4) | Percent change: −23 | | Percent change: −15 | | NS
220 Parallel | N=215 Mild/mod | | Non-inflammatory change (%) Between P-value: vs vehicle. | Mid (12) | Percent change: −40 | | Percent change: −25 | | 0.05
| | | Total lesions change (%) | Mid (12) | Percent change: −40 | | Percent change: −24 | | 0.05
220 Parallel | N=215 Mild/mod | E.05.01 | Inflammatory change (%) | Short (4) | Tretinoin (polyoprepolymer-2) Percent change: −20 | | Vehicle Percent change: −18 | | NS
| | | Non-inflammatory change (%) Between P-value: vs tretinoin (polyoprepolymer 2). | Short (4) | Percent change: −24 | | Percent change: −12 | | 0.05
| | | Total lesions change (%) | Short (4) | Percent change: −23 | | Percent change: −15 | | NS
| | | Inflammatory change (%) | Mid (12) | Percent change: −39 | | Percent change: −19 | | 0.05
| | | Non-inflammatory change (%) Between P-value: vs vehicle. | Mid (12) | Percent change: −41 | | Percent change: −25 | | 0.05
| | | Total lesions change (%) | Mid (12) | Percent change: −41 | | Percent change: −24 | | 0.05
219 ↑ Parallel | N=344 Mild/mod | E.05.01 | Inflammatory change (%) | Short (4) | Tretinoin + polyoprepolymer-2 Percent change: −15 | | Polyoprepolymer-2 Percent change: −11 | | NS
| | | Non-inflammatory change (%) | Short (4) | Percent change: −18 (21.) | | Percent change: −5 | | NS
| | | Total lesions change (%) | Short (4) | Percent change: −18 (21.) | | Percent change: −7
| | | Inflammatory change (%) | Mid (12) | Percent change: −46 | | Percent change: −32 (92.) | | NS
| | | Non-inflammatory change (%) | Mid (12) | Percent change: −44 (12.) | | Percent change: −28 | | NS
| | | Total lesions change (%) | Mid (12) | Percent change: −46 (12.) | | Percent change: −28 | | NS
38 ↓ Parallel | N=97 Mod | E.05.02 | Comedones (count) Count location: Entire face. Baseline counts: 25 (Target)/38 (Comparator) | Mid (12) | Tretinoin Percent Change*: −88 | .001 | Benzoyl peroxide Percent Change*: −53 | .001 | 0.01
| | | Papules (count) Count location: Entire face. Baseline counts: 42 (Target)/44 (Comparator) | Mid (12) | Percent Change*: −59 | .001 | Percent Change*: −38 | .001 | 0.01
38 ↓ Parallel | N=97 Mod | | Pustules (count) Count location: Entire face. Baseline counts: 8 (Target)/10 (Comparator) | Mid (12) | Percent Change*: −68 | .001 | Percent Change*: −63 | .001 | NS
221 ↓ Parallel | N=147 Mod | E.05.02 | Comedones (count) Baseline counts: 27 (Target)/23 (Comparator) | Short (6) | Tretinoin Percent Change*: −52 | | Benzoyl peroxide (acetone) Percent Change*: −61 | | NS
| | | Papules (count) Count location: Withouski/simon. Baseline counts: 8 (Target)/9 (Comparator) | Short (6) | Percent Change*: −25 | | Percent Change*: −67 | | NS
| | | Pustules (count) Baseline counts: 4 (Target)/4 (Comparator) | Short (6) | Percent Change*: −44 | | Percent Change*: −83 | | NS
| | | Comedones change (%) | Mid (8) | Percent change: −63 | | Percent change: −62 | | NS
| | | Papules change (%) | Mid (8) | Percent change: −29 | | Percent change: −56 | | 0.02
| | | Pustules change (%) | Mid (8) | Percent change: −48 | | Percent change: −80 | | NS
221 ↓ Parallel | N=147 Mod | E.05.02 | Comedones change (%) | Mid (8) | Tretinoin Percent change: −63 | | Benzoyl peroxide (alcohol) Percent change: −57 | | NS
| | | Papules change (%) | Mid (8) | Percent change: −29 | | Percent change: −56 | | 0.02
| | | Pustules change (%) | Mid (8) | Percent change: −48 | | Percent change: −79 | | NS
188 ↑ Parallel | N=289 | E.05.04 | Comedones (count/median) | Mid (12) | Tretinoin Measure: 18 | | Azelaic acid Measure: 22 | | NS
| | | Comedones (count) Baseline counts: 52 (Target)/50 (Comparator) | Long (20) | Percent Change*: −81 | | Percent Change*: −78 | | NS
316 Parallel | N=70 Mild | E.05.04 | Dryness (severity) | Short (4) | Tretinoin + vehicle Measure: 1 (1.6) | | Azelaic acid + glycolic acid Measure: 0 (1.6) | | 0.01
| | | Erythema (severity) | Short (4) | Measure: 1 (1.4) | | Measure: 1 (1.4) | | NS
316 Parallel | N=70 Mild | | Inflammatory change (%) | Short (4) | Percent change: −23 | | Percent change: −46 (36.)
| | | Non-inflammatory change (%) | Short (4) | Percent change: −32 | | Percent change: −18
| | | Papules change (%) | Short (4) | Percent change: −23 | | Percent change: −45 (43.)
| | | Scaling (severity) | Short (4) | Measure: 0 (0.9) | | Measure: 0 (0.9) | | 0.007
| | | Dryness (severity) | Mid (12) | Measure: 0 (0.9) | | Measure: 0 (0.9) | | NS
| | | Erythema (severity) | Mid (12) | Measure: 1 (2.) | | Measure: 0 (2.) | | 0.026
| | | Inflammatory change (%) | Mid (12) | Percent change: −28 (120.) | | Percent change: −55 (120.) | | NS
| | | Non-inflammatory change (%) | Mid (12) | Percent change: −46 | | Percent change: −47 | | NS
| | | Papules change (%) | Mid (12) | Percent change: −23 (132.) | | Percent change: −55 (132.) | | 0.03
| | | Scaling (severity) | Mid (12) | Measure: 0 (2.) | | Measure: 0 (2.) | | 0.001
58 ↓ Parallel | N=256 Sev | E.05.07 | Comedones severity (christiansen) Count location: Worst area. | Short (4) | Tretinoin (0.02%) Measure: 118 | | Tretinoin (0.05%) Measure: 120 | | 0.05
| | | Nodes+cysts (score) | Short (4) | Measure: 10 | | Measure: 20 | | NS
| | | Papules severity (christiansen) | Short (4) | Measure: 85 | | Measure: 92 | | NS
| | | Pustules (score) | Short (4) | Measure: 64 | | Measure: 71 | | NS
| | | Comedones (christiansen) | Mid (8) | Measure: 94 | | Measure: 89 | | 0.01
| | | Nodes+cysts (score) | Mid (8) | Measure: 9 | | Measure: 15 | | NS
| | | Papules severity (christiansen) | Mid (8) | Measure: 76 | | Measure: 61 | | NS
| | | Pustules (score) | Mid (8) | Measure: 42 | | Measure: 35 | | NS
198 ↑ Parallel | N=60 | E.05.07 | Comedones (count) Count location: 2.5 cm. Baseline counts: 29 (Target)/18 (Comparator) | Mid (12) | Tretinoin (0.025%) Percent Change*: −62 | | Tretinoin (0.05%) Percent Change*: −59
198 ↑ Parallel | N=60 | | Papules (count) Count location: 2.5 cm. Baseline counts: 10 (Target)/8 (Comparator) | Mid (12) | Percent Change*: −80 | | Percent Change*: −65
| | | Pustules (count) Count location: 2.5 cm. Baseline counts: 2 (Target)/3 (Comparator) | Mid (12) | Percent Change*: −87 | | Percent Change*: −85
| | | Severity/patient (vas) | Mid (12) | Measure: 20 | | Measure: 18
220 Parallel | N=215 Mild/mod | E.05.07 | Inflammatory change (%) | Short (4) | Tretinoin (polyoprepolymer-2) Percent change: −20 | | Tretinoin (ethanol) Percent change: −25 | | NS
| | | Non-inflammatory change (%) Between P-value: vs tretinoin (polyoprepolymer 2). | Short (4) | Percent change: −24 | | Percent change: −21 | | 0.05
| | | Total lesions change (%) | Short (4) | Percent change: −23 | | Percent change: −23 | | NS
| | | Inflammatory change (%) | Mid (12) | Percent change: −39 | | Percent change: −41 | | 0.05
| | | Non-inflammatory change (%) Between P-value: vs vehicle. | Mid (12) | Percent change: −41 | | Percent change: −40 | | 0.05
| | | Total lesions change (%) | Mid (12) | Percent change: −41 | | Percent change: −40 | | 0.05
219 ↑ Parallel | N=344 Mild/mod | E.05.07 | Inflammatory change (%) | Short (4) | Tretinoin + polyoprepolymer-2 Percent change: −15 | | Tretinoin Percent change: −22 | | NS
| | | Non-inflammatory change (%) | Short (4) | Percent change: −18 (21.) | | Percent change: −25 (21.) | | NS
| | | Total lesions change (%) | Short (4) | Percent change: −18 (21.) | | Percent change: −25 (21.)
| | | Inflammatory change (%) | Mid (12) | Percent change: −46 | | Percent change: −48 (92.) | | NS
| | | Non-inflammatory change (%) | Mid (12) | Percent change: −44 (12.) | | Percent change: −48 (12.) | | NS
| | | Total lesions change (%) | Mid (12) | Percent change: −46 (12.) | | Percent change: −49 (12.) | | NS
13 N=68 Parallel split face Mild/mod/sev | | E.05.08 | Change (gprg) | Short (4) | Tretinoin Measure: 98 | | Methyl prednisolone + neomycin Measure: 88
| | | Change (gprg) | Short (4) | Measure: 98 | | Measure: 88
| | | Change (gprg) | Mid (8) | Measure: 126 | | Measure: 120
| | | Change (gprg) | Mid (8) | Measure: 126 | | Measure: 120
| | | Comedones (count) | Mid (8) | Raw count: 7 | | Raw count: 7
| | | Comedones (count) | Mid (8) | Raw count: 7 | | Raw count: 7
37 ↑ Parallel | N=56 Mod | E.05.09 | Comedones change (count) Count location: 5cm diameter. Baseline counts: 6 (Target)/5 (Comparator) | Short (6) | Tretinoin Percent change*: −99 | | Chloramphenical + hydrocortisone Percent change*: −60
| | | Comedones change (count) | Short (6) | Percent change*: −99 | | Percent change*: −60
| | | Cysts change (count) Count location: 5 cm diameter. Baseline counts: 1 (Target)/0 (Comparator) | Short (6) | Percent change*: −67 | | Percent change*: −46 | | NS
| | | Cysts change (count) | Short (6) | Percent change*: −67 | | Percent change*: −46 | | NS
| | | Papules change (count) Count location: 5 cm diameter. Baseline counts: 7 (Target)/6 (Comparator) | Short (6) | Percent change*: −42 | | Percent change*: −27
| | | Papules change (count) | Short (6) | Percent change*: −42 | | Percent change*: −27
| | | Pustules change (count) Count location: 5 cm diameter. Baseline counts: 2 (Target)/2 (Comparator) | Short (6) | Percent change*: −62 | | Percent change*: −72
| | | Pustules change (count) | Short (6) | Percent change*: −62 | | Percent change*: −72
| | | Comedones change (count) Count location: 5 cm diameter. Baseline counts: 6 (Target)/5 (Comparator) | Mid (12) | Percent change*: −76 | .001 | Percent change*: −81 | .001 | NS
| | | Comedones change (count) | Mid (12) | Percent change*: −76 | .001 | Percent change*: −81 | .001 | NS
37 ↑ Parallel | N=56 Mod | | Cysts change (count) Count location: 5 cm diameter. Baseline counts: 1 (Target)/0 (Comparator) | Mid (12) | Percent change*: −82 | .001 | Percent change*: −46 | | NS
| | | Cysts change (count) | Mid (12) | Percent change*: −82 | .001 | Percent change*: −46 | | NS
| | | Overall change/patient (vas) Count location: 5 cm diameter. | Mid (12) | Measure: −4 (2.4) | .001 | Measure: −3 (4.6) | .001 | NS*
| | | Overall change/patient (vas) | Mid (12) | Measure: −4 (2.4) | .001 | Measure: −3 (4.6) | .001 | NS*
| | | Papules change (count) Count location: 5 cm diameter. Baseline counts: 7 (Target)/6 (Comparator) | Mid (12) | Percent change*: −47 | | Percent change*: −47 | | NS
| | | Papules change (count) | Mid (12) | Percent change*: −47 | | Percent change*: −47 | | NS
| | | Pustules change (count) Count location: 5 cm diameter. Baseline counts: 2 (Target)/2 (Comparator) | Mid (12) | Percent change*: −83 | .001 | Percent change*: −78 | .001 | NS
| | | Pustules change (count) | Mid (12) | Percent change*: −83 | .001 | Percent change*: −78 | .001 | NS
35 ↑ Parallel | N=72 Mild/mod | E.06.01 | Comedones (group count) Count location: Witkowski/simons. | Mid (12) | Vitamin A Percent Change*: −66 | | Vehicle Percent Change*: −42
| | | Comedones [female] (count) Count location: Witkowski/simons. Baseline counts: 272 (Target)/370 (Comparator) | Mid (12) | Percent Change*: −64 | | Percent Change*: −35
| | | Comedones [male] (count) Count location: Witkowski/simons. Baseline counts: 1042 (Target)/722 (Comparator) | Mid (12) | Percent Change*: −67 | | Percent Change*: −46
| | | Papules (group count) Count location: Witkowski/simons. | Mid (12) | Percent Change*: −26 | | Percent Change*: −49
| | | Papules [female] (group count) | Mid (12) | Percent Change*: −12 | | Percent Change*: −13
| | | Papules [male] (group count) | Mid (12) | Percent Change*: −66 | | Percent Change*: −30
| | | Pustules (total count) | Mid (12) | Percent Change*: −68 | | Percent Change*: −67
| | | Pustules [female] (total count) | Mid (12) | Percent Change*: −94 | | Percent Change*: −92
| | | Pustules [male] (total count) | Mid (12) | Percent Change*: −60 | | Percent Change*: −62
272 Parallel | N=189 | E.06.02 | Total lesions change (%) Count location: Left side. | Long (14) | Vitamin A Percent change: −62 | | Sulfur + resorcinol Percent change: −16

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., - our assessment of entry severity of study patients. “P”- parallel study, “S”- split face design. TARGET and COMPARATOR: “Percent change”- an outcome derived from individual final and baseline measures; “Percent change*”- we calculated a group-based percentage change; “Change” - raw difference from baseline; “Change*” - calculated change; “Measure” - an outcome measure with no baseline comparison. SD: standard deviation. WITHIN P: P-value with respect to baseline in one arm. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table E3: DISCRETE outcomes for class RETINOID (TOPICAL)

Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Treatment | Comparator | Between P-value
Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Attribute: Number of patients | Attribute: Number of patients | Between P-value
338 ↑ Parallel Mild/mod/sev N=72 | E.01.01 | Severe erythema | Mid (12) | Adapalene (0.03%) Present 0 Absent 24 | Adapalene (0.1%) Present 1 Absent 23 | NS
49 ↑ Parallel split face Mild/mod N=15 | E.01.02 | Burning severity (patient) | Short (2) | Adapalene Very severe 0 Severe 0 Moderate 5 Slight 0 | Tretinoin Very severe 0 Severe 4 Moderate 6 Slight 1 | 0.02
| | Desquamation severity (invesigator) | Short (2) | None 10 Very severe 0 Severe 1 Moderate 5 Slight 7 | None 4 Very severe 0 Severe 2 Moderate 6 Slight 5 | 0.04
| | Edema severity (invesigator) | Short (2) | None 2 Very severe 0 Severe 0 Moderate 0 Slight 1 | None 2 Very severe 0 Severe 0 Moderate 0 Slight 1 | NS
| | Erythema severity (invesigator) | Short (2) | None 14 Very severe 0 Severe 0 Moderate 1 Slight 8 | None 14 Very severe 0 Severe 0 Moderate 5 Slight 6 | NS
| | Papules severity (invesigator) | Short (2) | None 6 Very severe 0 Severe 1 Moderate 7 Slight 6 | None 4 Very severe 0 Severe 0 Moderate 7 Slight 7 | NS
49 ↑ Parallel split face Mild/mod N=15 | | Pruritis severity (patient) | Short (2) | None 1 Very severe 0 Severe 0 Moderate 2 Slight 7 | None 1 Very severe 0 Severe 0 Moderate 6 Slight 7 | 0.02
| | Tightness severity (patient) | Short (2) | None 6 Very severe 0 Severe 1 Moderate 1 Slight 9 | None 2 Very severe 0 Severe 1 Moderate 6 Slight 5 | 0.02
| | Vesicle severity (invesigator) | Short (2) | None 4 Very severe 0 Severe 0 Moderate 0 Slight 0 | None 3 Very severe 0 Severe 0 Moderate 0 Slight 0 | NS
63 ↑ Parallel Mild/sev N=591 | | Adverse reations Between P-value: compare of total number reports | Mid (12) | None 15 Irritation, erythema, dermatitis 6 Dry skin 4 Skin discomfort, pruritis 6 Acne flare 3 | None 15 Irritation, erythema, dermatitis 12 Dry skin 13 Skin discomfort, pruritis 10 Acne flare 2 | 0.05
| | Discontinuation due to side effects | Mid (12) | Infection, herpes 0 Sunburn 0 total cutaneous 19 Acne flare 2 Irritation 2 Dry skin 0 | Infection, herpes 1 Sunburn 1 total cutaneous 39 Acne flare 1 Irritation 4 Dry skin 2
80 Parallel N=268 | | Burning | Short (2) | Moderate 5 Severe 3 Other 129 | Moderate 34 Severe 5 Other 95 | 0.01
| | Dryness | Short (2) | Moderate 10 Severe 5 Other 119 | Moderate 17 Severe 5 Other 112
| | Scaling | Short (2) | Moderate 17 Severe 5 Other 112 | Moderate 26 Severe 11 Other 97
80 ↑ Parallel N=268 | | Burning | Mid (12) | Moderate 1 Severe 0 Other 133 | Moderate 9 Severe 2 Other 123 | 0.01
| | Dryness | Mid (12) | Moderate 4 Severe 3 Other 127 | Moderate 16 Severe 4 Other 114 | 0.05
| | Scaling | Mid (12) | Moderate 9 Severe 3 Other 122 | Moderate 12 Severe 2 Other 115 | 0.05
93 ↑ Parallel split face Mild/mod N=100 | | Inter-treatment preference | Short (4) | Easier to apply 80 Quickest to apply 58 Best smell 78 Feels the best 77 | Easier to apply 20 Quickest to apply 48 Best smell 22 Feels the best 24 | 0.001
| | Intolerannce | Short (4) | Feels less greasy 66 Prefer 68 Intolerance 32 | Feels less greasy 37 Prefer 38 Intolerance 70 | 0.001
100 Parallel Mod N=297 | | Comedones change (count) | Short (4) | 75% or greater improvement 14 Less than 75% improvement 97 | 75% or greater improvement 10 Less than 75% improvement 106 | NS
| | Comedones change (count) | Mid (12) | 75% or greater improvement 36 Less than 75% improvement 75 | 75% or greater improvement 26 Less than 75% improvement 100 | NS
| | Dose regime altered | Mid (12) | Regime altered 25 | Regime altered 20
| | Side effects Between P-value: for burning and puritis | Mid (12) | Discontinuation drug related 8 Discontinuation probably not drug related 4 Skin discomfort 16 | Discontinuation drug related 4 Discontinuation probably not drug related 2 Skin discomfort 9 | 0.05
140 Parallel Mild/mod N=105 | | Side effects | Mid (12) | Erythema 6 Dryness 11 Scaling 8 Immediate burning 2 | Erythema 16 Dryness 15 Scaling 19 Immediate burning 19
| | Withdrawal due to side effects | Mid (12) | Persistent burning 3 Irritation 1 | Persistent burning 12 Irritation 3
306 ↑ Parallel Mod N=288 | | Severity change | Mid (12) | Non-inflammatory lesions 31 Total lesions 29 Inflammatory lesions 32 | Non-inflammatory lesions 18 Total lesions 18 Inflammatory lesions 32
338 ↑ Parallel Mild/mod/sev N=72 | E.01.02 | Severe erythema | Mid (12) | Adapalene (0.03%) Present 0 Absent 24 | Tretinoin Present 1 Absent 23 | NS
338 ↑ Parallel Mild/mod/sev N=72 | E.01.02 | Severe erythema | Mid (12) | Adapalene (0.1%) Present 1 Absent 23 | Tretinoin Present 1 Absent 23 | NS
54 ↑ Parallel N=313 | E.01.01 | Erythema score | Long (14) | Isotretinoin Grade 0 31 Grade 1 67 Grade 2 27 Grade 3 5 | Vehicle Grade 0 52 Grade 1 67 Grade 2 16 Grade 3 3
| | Peeling score | Long (14) | Grade 4 0 Grade 0 38 Grade 1 69 Grade 2 20 Grade 3 3 | Grade 4 0 Grade 0 67 Grade 1 58 Grade 2 12 Grade 3 1
173 Parallel Mild/mod/sev N=77 | | Local reactions I | Mid (12) | Grade 4 0 Scaling 7 Stinging 0 Itching 1 Peeling 4 | Grade 4 0 Scaling 3 Stinging 2 Itching 0 Peeling 3
| | Local reactions II | Mid (12) | Erythema 10 Burning 4 soreness 4 Dryness 3 Roughness 0 | Erythema 1 Burning 0 soreness 0 Dryness 0 Roughness 1
202 Parallel Mild/mod N=82 | E.02.01 | Side effects | Mid (12) | Isotretinoin (0.05%) Erythema (withdraw) 1 | Vehicle Erythema (withdraw) 0 | 0.05
202 Parallel Mild/mod N=82 | E.02.01 | Side effects | Mid (12) | Isotretinoin (0.1%) Erythema (withdraw) 0 | Vehicle Erythema (withdraw) 0 | 0.05
173 ↑ Parallel Mild/mod N=77 | E.02.02 | Local reactions I | Mid (12) | Isotretinoin Scaling 7 Stinging 0 Itching 1 Peeling 4 | Benzoyl peroxide Scaling 7 Stinging 1 Itching 3 Peeling 2
| | Local reactions II | Mid (12) | Erythema 10 Burning 4 soreness 4 Dryness 3 Roughness 0 | Erythema 10 Burning 3 soreness 3 Dryness 5 Roughness 1
202 Parallel Mild/mod N=82 | E.02.03 | Side effects | Mid (12) | Isotretinoin (0.05%) Erythema (withdraw) 1 | Isotretinoin (0.1%) Erythema (withdraw) 0 | 0.05
90 ↑ Parallel Mod N=30 | E.02.04 | Irritation | Mid (12) | Isotretinoin Present 7 | Tretinoin Present 0
| | Stinging, erythema, desquamation | Mid (12) | Present 0 | Present 10
98 Parallel Mod N=30 | | Comedones change | Mid (12) | 75% or greater reduction 3 25-75% reduction 2 25% or less reduction 3 | 75% or greater reduction 3 25-75% reduction 1 25% or less reduction 4 | NS
98 Parallel N=18 | | Inflammatory change (%) | Mid (12) | 75% or greater reduction 3 25-75% reduction 3 25% or less reduction 2 | 75% or greater reduction 2 25-75% reduction 3 25% or less reduction 3 | NS
| | Total lesions change (%) | Mid (12) | 75% or greater reduction 2 25-75% reduction 5 25% or less reduction 1 | 75% or greater reduction 2 25-75% reduction 4 25% or less reduction 2 | NS
60 Parallel Mild/mod N=257 | E.03.01 | Overall change/physician | Mid (8) | Motretinide Worse 2 No change 13 Insufficient 11 Moderate 27 | Vehicle Worse 8 No change 12 Insufficient 9 Moderate 21 | NS
| | Reduction in application due to side effects | Mid (8) | Good 19 Excellent 3 Reduced # application 10 | Good 17 Excellent 2 Reduced # application 7 | NS
| | Side effects | Mid (8) | Pruritis 34 Burning 25 Erythema + desquamation 23 Desquamation to erythema 10 | Pruritis 26 Burning 23 Erythema + desquamation 16 Desquamation to erythema 12 | NS
| | Total lesions change | Mid (8) | Erythema + desquamation 19 No side effects 23 local irritation (withdraw) 0 −1 (worse) 6 0% 1 1-49% 23 50-74% 27 | Erythema + desquamation 14 No side effects 30 local irritation (withdraw) 0 −1 (worse) 4 0% 4 1-49% 22 50--74% 23 | NS
61 ↓ Parallel N=19 | | Local reactions | Mid (8) | 57-99% 18 100%(eradication) 2 Desquamation without erythema 1 Desquamation without erythema 3 Burning 2 Pruritis 4 | 57-99% 14 100 (eradication) 1 Desquamation without erythema 2 Desquamation without erythema 4 Burning 4 Pruritis 7 | NS
253 ↑ Parallel Mod/sev N=60 | E.03.02 | Overall change/physician | Mid (8) | Motretinide (bid) Excellent 2 Good 6 Moderate 8 Insufficient 2 | Motretinide (qd) Excellent 1 Good 8 Moderate 6 Insufficient 2 | NS
| | | | Unchanged 1 Aggravated | Unchanged 1 Aggravated
59 ↑ Parallel Mild N=37 | E.03.03 | Burning | Mid (8) | Motretinide Present 2 Withdraw 2 | Tretinoin Present 9 Withdraw 2 | 0.05
| | Erythema desquamation | Mid (8) | Present 7 | Present 14 | 0.05
| | Total lesions | Mid (8) | Complete 6 | Complete 6 | NS
60 Parallel Mild/mod N=257 | | Overall change/physician | Mid (8) | Worse 2 No change 13 Insufficient 11 Moderate 27 | Worse 0 No change 3 Insufficient 9 Moderate 11 | NS
| | Reduction in application due to side effects | Mid (8) | Good 19 Excellent 3 Reduced # application 10 | Good 34 Excellent 13 Reduced # application 43 | NS
| | Side effects | Mid (8) | Pruritis 34 Burning 25 Erythema + desquamation 23 Desquamation to erythema 10 | Pruritis 62 Burning 69 Erythema + desquamation 76 Desquamation to erythema 0 | NS
| | Total lesions change | Mid (8) | Erythema no desquamation. 19 No side effects 23 local irritation (withdraw) 0 −1 (worse) 6 0% 1 1-49% 23 50-74% 27 | Erythema no desquamation. 6 No side effects 0 local irritation (withdraw) 2 −1 (worse) 0 0% 2 1-49% 12 50-74% 19 | NS
253 ↑ Parallel Mod/sev N=60 | E.03.03 | Overall change/physician | Mid (8) | 57-99% 18 100%(eradication) 2 Motretinide (bid) Excellent 2 Good 6 Moderate 8 Insufficient 2 | 57-99% 29 100%(eradication) 8 Tretinoin Excellent 3 Good 9 Moderate 5 Insufficient 1 | NS
253 ↑ Parallel Mod/sev N=60 | E.03.03 | Overall change/physician | Mid (8) | Unchanged 1 Aggravated Motretinide (qd) Excellent 1 Good 8 Moderate 6 Insuffient 2 | Unchanged 1 Aggravated Tretinoin Excellent 1 Good 9 Moderate 5 Insuffient 1 | NS
| | | | Unchanged 1 Aggravated | Unchanged 1 Aggravated
145 ↑ Parallel Mild/mod N=29 | E.04.01 | Adverse reaction | Long (18) | Retinyl beta-glucuronide Any 0 | Vehicle Any 0
| | Non-responders | Long (18) | Non-responders 1 | Non-responders 4
146 ↑ Parallel Mild/mod N=15 | E.04.02 | Adverse reaction | Long (28) | Retinyl beta-glucuronide Erythema, drying, peeling, cracking Erythema, drying, peeling, cracking 0 | Tretinoin Erythema, drying, peeling, cracking Erythema, drying, peeling, cracking 5
| | Non-responders | Long (28) | Non-responders 1 | Non-responders 0
219 ↑ Parallel Mild/mod N=344 | E.05.01 | Side effects | Short (4) | Tretinoin Peeling 18 Burning 14 Erythema 14 Tightness 34 | Polyoprepolymer-2 Peeling 6 Burning 7 Erythema 9 Tightness 20 | NS
| | | | Itching 16 Dryness 26 | Itching 7 Dryness 7
219 ↑ Parallel Mild/mod N=344 | | Overall change/physician | Mid (12) | Excellent 25 Fair to good 60 | Excellent 10 Fair to good 30 | NS
| | Side effects | Mid (12) | Peeling 9 Burning 8 Erythema 9 Tightness 24 | Peeling 2 Burning 1 Erythema 2 Tightness 13 | NS
60 Parallel Mild/mod N=257 | E.05.01 | Overall change/physician | Mid (8) | Itching 15 Dryness 18 Tretinoin Worse 0 No change 3 Insufficient 9 Moderate 11 | Itching 4 Dryness 2 Vehicle Worse 8 No change 12 Insufficient 9 Moderate 21 | 0.0005
| | Reduction in application due to side effects | Mid (8) | Good 34 Excellent 13 Reduced # application 43 | Good 17 Excellent 2 Reduced # application 7 | 0.0005
| | Side effects | Mid (8) | Pruritis 62 Burning 69 Erythema + desquamation 76 Desquamation to erythema 0 | Pruritis 26 Burning 23 Erythema + desquamation 16 Desquamation to erythema 12 | 0.0005
| | Total lesions change | Mid (8) | Erythema no desquamation. 6 No side effects 0 local irritation (withdraw) 2 −1 (worse) 0 0% 2 1-49% 12 50-74% 19 | Erythema no desquamation. 14 No side effects 30 local irritation (withdraw) 0 −1 (worse) 4 0% 4 1-49% 22 50--74% 23 | 0.0005
270 ↓ Parallel N=61 | | Comedones severity | Mid (8) | 57-99% 29 100% (eradication) 8 Marked 12 Moderate 11 Slight 3 None 4 | 57-99% 14 100 (eradication) 1 Marked 0 Moderate 2 Slight 17 None 8
| | Improvement in papules | Mid (8) | Worse 0 Marked 2 Moderate 12 Slight 7 None 5 | Worse 0 Marked 0 Moderate 0 Slight 7 None 20
| | Improvement on pustules | Mid (8) | Worse 0 Marked 3 Moderate 4 Slight 12 None 5 | Worse 0 Marked 0 Moderate 0 Slight 5 None 19
| | Overall change | Mid (8) | Worse 2 Excellent 8 Good 9 Fair 7 Poor 3 | Worse 3 Excellent 0 Good 0 Fair 7 Poor 20
58 ↓ Parallel Sev N=256 | E.05.01 | Side effects Between P-value: with respect to placebo | Short (2) | Tretinoin (0.02%) Erythema/peeling 58 | Vehicle Erythema/peeling 31 | 0.001
| | Side effects | Mid (8) | Erythema/peeling 14 | Erythema/peeling 4
198 ↑ Parallel N=60 | E.05.01 | Clinical assessment | Mid (12) | Tretinoin (0.025%) Marked improvement 10 Improved 11 Slight improvement 1 No change 0 | Vehicle Marked improvement 0 Improved 0 Slight improvement 1 No change 17
| | Side effects | Mid (12) | Worse 0 Soreness, erythema, irritation (withdraw) 0 Soreness, erythema, irritation 7 None 15 | Worse 1 Soreness, erythema, irritation (withdraw) 0 Soreness, erythema, irritation 0 None 20
58 ↓ Parallel Sev N=256 | E.05.01 | Side effects | Short (2) | Tretinoin (0.05%) Erythema/peeling 70 | Vehicle Erythema/peeling 31 | 0.001
| | Side effects | Mid (8) | Erythema/peeling 16 | Erythema/peeling 4
198 ↑ Parallel N=60 | | Clinical assessment | Mid (12) | Marked improvement 3 Improved 11 Slight improvement 3 No change 0 | Marked improvement 0 Improved 0 Slight improvement 1 No change 17
| | Side effects | Mid (12) | Worse 0 Soreness, erythema, irritation (withdraw) 1 Soreness, erythema, irritation 10 None 6 | Worse 1 Soreness, erythema, irritation (withdraw) 0 Soreness, erythema, irritation 0 None 20
220 Parallel Mild/mod N=215 | E.05.01 | Adverse effect | Short (4) | Tretinoin (ethanol) Itching 9 Tightness 15 Burning 10 Erythema 28 | Vehicle Itching 4 Tightness 10 Burning 3 Erythema 13
| | Any adverse outcome | Short (4) | Peeling 26 Dryness 19 Skin/appendage adverse reaction 13 | Peeling 4 Dryness 8 Skin/appendage adverse reaction 2
| | Adverse effects | Mid (12) | Itching 7 Tightness 9 Burning 7 Erythema 15 | Itching 0 Tightness 6 Burning 1 Erythema 5
| | Dry skin Between P-value: .05 vs. tretinoin (polyolprepolymer-2), .05 vs. vehicle | Mid (12) | Peeling 15 Dryness 15 Present 6 | Peeling 2 Dryness 5 Present 0
| | Eruption | Mid (12) | Present 9 | Present 2 | NS
| | Other skin symptoms | Mid (12) | Severe (withdraw) 2 Stinging 1 | Severe (withdraw) 0 Stinging 0
220 Parallel Mild/mod N=215 | | Systemic adverse effects | Mid (12) | Any adverse event 29 | Any adverse event 25 | NS
220 Parallel Mild/mod N=215 | E.05.01 | Adverse effect | Short (4) | Tretinoin (polyoprepolymer-2) Itching 11 Tightness 13 Burning 6 Erythema 16 | Vehicle Itching 4 Tightness 10 Burning 3 Erythema 13
| | Any adverse outcome | Short (4) | Peeling 12 Dryness 10 Skin/appendage adverse reaction 11 | Peeling 4 Dryness 8 Skin/appendage adverse reaction 2
| | Adverse effects | Mid (12) | Itching 4 Tightness 6 Burning 3 Erythema 7 | Itching 0 Tightness 6 Burning 1 Erythema 5
| | Dry skin Between P-value: vs. tretinoin (ethanol) | Mid (12) | Peeling 5 Dryness 6 Present 1 | Peeling 2 Dryness 5 Present 0 | 0.05
| | Eruption | Mid (12) | Present 8 | Present 2 | NS
| | Other skin symptoms | Mid (12) | Severe (withdraw) 0 Stinging 3 | Severe (withdraw) 0 Stinging 0
| | Systemic adverse effects | Mid (12) | Any adverse event 30 | Any adverse event 25 | NS
219 ↑ Parallel Mild/mod N=344 | E.05.01 | Side effects | Short (4) | Tretinoin + polyoprepolymer-2 Peeling 26 Burning 20 Erythema 20 Tightness 40 | Polyoprepolymer-2 Peeling 6 Burning 7 Erythema 9 Tightness 20 | NS
| | Overall change/physician | Mid (12) | Itching 15 Dryness 26 Excellent 29 Fair to good 52 | Itching 7 Dryness 7 Excellent 10 Fair to good 30 | NS
219 ↑ Parallel Mild/mod N=344 | | Side effects | Mid (12) | Peeling 10 Burning 8 Erythema 8 Tightness 18 | Peeling 2 Burning 1 Erythema 2 Tightness 13 | NS
| | | | Itching 9 Dryness 15 | Itching 9 Dryness 15
38 ↓ Parallel Mod N=97 | E.05.02 | Side effects | | Tretinoin Erythema and irritation 1 Slight stinging 1 Erythema and soreness 1 | Benzoyl peroxide Soreness 1 Pruritis 1
| | Overall change/patient | Mid (12) | Improvement 35 No improvement 9 | Improvement 14 No improvement 30 | 0.001
| | Overall change/physician | Mid (12) | Improvement 38 No improvement 6 | Improvement 19 No improvement 25 | 0.001
221 ↓ Parallel Mod N=147 | E.05.02 | Severity change | Mid (8) | Tretinoin Excellent 15 Good 19 Fair 13 Poor 8 | Benzoyl peroxide (acetone) Excellent 20 Good 15 Fair 11 Poor 8 | NS
221 ↓ Parallel Mod N=147 | E.05.02 | Adverse reaction | Mid (8) | Tretinoin Burning, erythema, peeling, severe 10 None 44 | Benzoyl peroxide (alcohol) Burning, erythema, peeling, severe 20 None 18
| | Severity change | Mid (8) | Excellent 15 Good 19 Fair 13 Poor 8 | Excellent 11 Good 8 Fair 11 Poor 8 | NS
188 ↑ Parallel N=289 | E.05.04 | Erythema | Long (24) | Tretinoin Present 40 Absent 106 | Azelaic acid Present 25 Absent 118
188 ↑ Parallel N=289 | | Overall change/physician | Long (24) | Excellent-good 60 Moderate 18 Poor 20 | Excellent-good 58 Moderate 20 Poor 21 | NS
| | Scaling | Long (24) | Present 42 Absent 104 | Present 24 Absent 119
316 Parallel Mild N=70 | E.05.04 | Side effects (patient assessment) Between P-value: Dryness .001/Redness ..037/Peeling .001 | Mid (12) | Tretinoin + vehicle Dryness 10 Redness 8 Peeling 5 | Azelaic acid + glycolic acid Dryness 0 Redness 2 Peeling 0
58 ↓ Parallel Sev N=256 | E.05.07 | Side effects Between P-value: with respect to placebo | Short (2) | Tretinoin (0.02%) Erythema/peeling 58 | Tretinoin (0.05%) Erythema/peeling 70 | 0.001
| | Side effects | Mid (8) | Erythema/peeling 14 | Erythema/peeling 16
198 ↑ Parallel N=60 | E.05.07 | Clinical assessment | Mid (12) | Tretinoin (0.025%) Marked improvement 10 Improved 11 Slight improvement 1 No change 0 | Tretinoin (0.05%) Marked improvement 3 Improved 11 Slight improvement 3 No change 0
| | Side effects | Mid (12) | Worse 0 Soreness, erythema, irritation (withdraw) 0 Soreness, erythema, irritation 7 None 15 | Worse 0 Soreness, erythema, irritation (withdraw) 1 Soreness, erythema, irritation 10 None 6
34 ↑ Parallel Mild/mod N=75 | E.06.01 | Response | Mid (12) | Vitamin A Poor 9 Fair 7 Good 14 Excellent 20 | Vehicle Poor 11 Fair 6 Good 4 Excellent 4
| | Side effects | Mid (12) | Erythema 47 | Erythema & peeling 0
35 ↑ Parallel Mild/mod N=72 | | Overall change | Mid (12) | Excellent 10 Good 12 Fair 6 Poor 3 | Excellent 5 Good 8 Fair 11 Poor 10
| | Overall change [female] | Mid (12) | Excellent 2 Good 7 Fair 1 Poor 1 | Excellent 1 Good 5 Fair 3 Poor 3 | 0.018
| | Overall change [male] | Mid (12) | Excellent 8 Good 5 Fair 5 Poor 2 | Excellent 4 Good 3 Fair 8 Poor 7 | 0.04

TRIAL: ↑↓ -presence of positive or negative methodological features (see Summary Table). “Mild/mod,” etc., -our assessment of entry severity of study patients. “P”- to parallel study, “S”-split face design. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table G1. Articles/arms for class RETINOID (TOPICAL)/ANTI-BACTERIAL (TOPICAL)

Comp-Trial | | | TARGET | HEADING | | COMPARATOR | | Outcome Table(s)
Comp-Trial | | Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment | Outcome Table(s)
G.01.01 | 238 | Tretinoin Erythromycin | 0.05 % topical qhs. 2 % topical bid. | Purpose^®^ soap. | Vehicle | No dose information. | Purpose^®^ soap. | Discrete (M)
G.02.01 | 45 | Clindamycin phosphate Tretinoin | 1.2 % topical qd. 0.025 % topical qd. | Calibrated pump. Small initial doses. | Clindamycin phosphate | No dose information. | | Continuous
| 46 | Clindamycin phosphate Tretinoin | 1.2 % topical qd. 0.025 % topical qd. | Calibrated pump. Small initial doses. | Clindamycin phosphate | No dose information. | | Continuous
| 47 | Clindamycin phosphate Tretinoin | 1.2 % topical qd. 0.025 % topical qd. | Calibrated pump. Small initial doses. | Clindamycin | 1.2 % topical qd. | | Continuous
| 283 | Clindamycin Tretinoin | 1 % topical qd. 0.025 % topical qd. | Tretinoin applied nightly and clinda applied in morning. Purpose^®^ with medication application.. | Clindamycin phosphate | 1 % topical bid. | Purpose soap with medicate application. | Continuous Discrete
G.02.02 | 42 | Clindamycin phosphate Tretinoin | 1.2 % topical qd. 0.025 % topical qd. | Clibrated pump. Small initial doses. | Tretinoin | 0.025 % topical qd. | Different gel from Velac^®^. | Continuous
| 43 | Clindamycin Tretinoin | 1.2 % topical qd. 0.025 % topical qd. | Calibrated pump. Small initial doses. | Tretinoin | 0.025 % topical qd. | Different gel from Velac^®^. | Continuous
| 44 | Clindamycin phosphate Tretinoin | 1.2 % topical qd. 0.025 % topical qd. | Clibrated pump. Small until doses. | Tretinoin | 0.025 % topical qd. | Velac^®^ gel. | Continuous

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table G2. CONTINUOUS outcomes for class RETINOID (TOPICAL))/ANTI-BACTERIAL (TOPICAL)

Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Target | | Comparator | | Between P-value
Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Data Type: Mean (SD) | Within P | Data Type: Mean (SD) | Within P | Between P-value
| | G.02.01 | | | Tretinoin + clindamycin | | Clindamycin
46 Parallel | N=40 Mod/sev | | Severity (cook) | Short (4) | Measure: 4 | | Measure: 3
45 | N=209 | | Severity (cook) | Short (4) | Measure: 4 | | Measure: 3 | | NS
47 | N=162 | | Severity (cook) | Short (4) | Measure: 4 | | Measure: 4
283 Parallel | N=64 Mild/mod/sev | | Dryness (severity) | Short (6) | Measure: 1 | | Measure: 0
| | | Erythema (severity) | Short (6) | Measure: 1 | | Measure: 0 | | NS
| | | Comedones change (%) Count location: Unspecified. Between P-value: T + C vs C: significant. | Mid (8) | Percent change: −48 | | Percent change: −20 | | ‘Significant’
| | | Dryness (severity) | Mid (8) | Measure: 2 | | Measure: 0 | | NS
| | | Erythema (severity) | Mid (8) | Measure: 1 | | Measure: 0 | | NS
| | | Papules change (%) Count location: Unspecified. | Mid (8) | Percent change: −52 | | Percent change: −53 | | NS
| | | Pustules change (%) | Mid (8) | Percent change: −60 | | Percent change: −62 | | NS
| | | Severity (cook) | Mid (8) | Measure: 4 | | Measure: 3 | | NS
47 Parallel | N=162 Mod/sev | | Inflammatory change (%) | Mid (12) | Percent change: −64 | | Percent change: −57 | | NS
46 | N=40 | | Inflammatory change (%) | Mid (12) | Percent change: −89 | | Percent change: −71 | | NS
45 | N=209 | | Inflammatory change (%) | Mid (12) | Percent change: −76 | | Percent change: −58 | | NS
47 | N=162 | | Non-inflammatory change (%) | Mid (12) | Percent change: −64 | | Percent change: −51 | | 0.04
46 | N=40 | | Non-inflammatory change (%) | Mid (12) | Percent change: −69 | | Percent change: −43 | | NS
45 | N=209 | | Non-inflammatory change (%) | Mid (12) | Percent change: −69 | | Percent change: −61 | | 0.05
| | | Severity (cook) | Mid (12) | Measure: 2 | | Measure: 2 | | 0.007
47 | N=162 | | Severity (cook) | Mid (12) | Measure: 2 | | Measure: 2 | | 0.001
46 | N=40 | | Severity (cook) | Mid (12) | Measure: 2 | | Measure: 2 | | NS
| | G.02.02 | | | Tretinoin + Clindamycin | | Tretinoin
42 Parallel | N=40 Mod/sev | | Severity (cook) | Short (4) | Measure: 3 | | Measure: 3 | | NS
43 | N=161 | | Severity (cook) | Short (4) | Measure: 4 | | Measure: 4 | | NS
44 | N=157 | | Severity (cook) | Short (4) | Measure: 4 | | Measure: 4 | | NS
43 | N=161 | | Inflammatory change (%) Count location: Unspecified. | Mid (12) | Percent change: −72 | | Percent change: −55 | | 0.001
42 | N=40 | | Inflammatory change (%) | Mid (12) | Percent change: −81 | | Percent change: −53 | | 0.04
44 | N=157 | | Inflammatory change (%) | Mid (12) | Percent change: −62 | | Percent change: −48 | | NS
42 | N=40 | | Non-inflammatory change (%) | Mid (12) | Percent change: −75 | | Percent change: −64 | | NS
44 | N=157 | | Non-inflammatory change (%) | Mid (12) | Percent change: −68 | | Percent change: −65 | | NS
43 | N=161 | | Non-inflammatory change (%) | Mid (12) | Percent change: −59 | | Percent change: −53 | | NS
42 | N=40 | | Severity (cook) | Mid (12) | Measure: 1 | | Measure: 2
43 | N=161 | | Severity (cook) | Mid (12) | Measure: 2 | | Measure: 3 | | 0.009
44 | N=157 | | Severity (Cook) | Mid (12) | Measure: 2 | | Measure: 2 | | NS

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., - our assessment of entry severity of study patients. “P”- parallel study, “S”- split face design. TARGET and COMPARATOR: “Percent change”- an outcome derived from individual final and baseline measures; “Percent change*”- we calculated a group-based percentage change; “Change” - raw difference from baseline; “Change*” - calculated change; “Measure” - an outcome measure with no baseline comparison. SD: standard deviation. WITHIN P: P-value with respect to baseline in one arm. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table H1. Articles/arms for class ANTI-BACTERIAL (ORAL)

Comp-Trial | | TARGET | | HEADING | | COMPARATOR | | Outcome Table(s)
Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment
H.01.01 | 56 | Clindamycin | 150 mg oral bid. | Qid 1 week, tid 1 week, then bid. Chosen by patient and included: antibacterial soaps, antibacterial cleanser, various peeling agents. Encouraged not to start/stop ancillary treatment after initiation of study. | Vehicle | No dose information. | Qid 1 week, tid 1 week, then bid. Chosen by patient and included: antibacterial soaps, antibacterial cleanser, various peeling agents. Encouraged not to start/stop ancillary treatment after initiation of study. | Continuous Discrete
H.01.02 | 265 | Clindamycin | 150 mg oral (qid 1 week; tid second week then bid) | Pernox^®^ nightly; Transact bid. | Tetracycline | 250 mg oral (qid one week; tid week 2 then bid) | Pernox^®^ nightly; Transact bid. | Continuous Discrete
| 275 | Clindamycin hydrochloride | 150 mg oral qd. | Non-antibacterial soap and shampoo. | Tetracycline hydrochloride | 250 mg oral bid. | Non-antibacterial soap and shampoo. | Discrete
H.02.01 | 71 | Demethylchlortetracycline | 150 mg oral qid. | | Vehicle | No dose information. | | Discrete
| 162 | Demethylchlortetracycline | 150 mg oral qid. | Well-known soap and bedtime lotion. | Placebo | No dose information. | | Discrete
| 192 | Demethylchlortetracycline | 150 mg oral qd. | Supply taken until exhausted. Common acne cleansers and drying lotions. | Placebo | No dose information. | Supply taken until exhausted (24 capsules). Common acne cleansers and drying lotions. | Discrete
| 193 | Demethylchlortetracycline | 150 mg oral qhs. | 24 tabs provided and told to complete. | Placebo | No dose information. | | Discrete
| 312 | Demethylchlortetracycline | 150 mg oral qid. | After meals. | Placebo | No dose information. | 1/2 hour after meals. | Continuous Discrete
H.02.02 | 312 | Demethylchlortetracycline | 150 mg oral qid. | After meals. | Phenethicillin | 250 mg oral qid. | 1/2 hr. Before meals. | Continuous Discrete
H.02.03 | 70 | Demethylchlortetracycline | 150 mg oral tid. | Qid until response, then reduced to tid, bid, qd, as tolerated, and until a total of 300 capsules used. | Tetracycline | 250 mg oral tid. | | Discrete
| 71 | Demethylchlortetracycline | 150 mg oral qid. | | Tetracycline hydrochloride | 250 mg oral qid. | | Discrete
H.03.01 | 273 | Doxycycline | 200 mg oral qd. | 2 capsules in A.M. | Placebo | No dose information. | 2 capsules in A.M. | Continuous Discrete
H.03.02 | 1 | Doxycycline | 50 mg oral qd. | | Fusidin | 2 % topical qhs. | | Continuous Discrete
H.03.03 | 25 | Placebo Doxycycline | No dose information. 100 mg oral (qod) | For 2 weeks bid; then one cap 90d. Tioxolon^®^ powder 0.1%. | Placebo Erythromycin stearate | No dose information. 250 mg oral bid. | 500 mg bid x 2 weeks; then 250 mg bid x 4. Tioxolon^®^ powder 0.1%. | Continuous
H.03.04 | 155 | Doxycyline | 50 mg oral qd. | Chlorhexidine 4% + benzoyl peroxide 5%.. | Minocycline | 50 mg oral bid. | Chlorhexidine 4% + benzyol peroxide 5%.. | Continuous Discrete
| 257 | Placebo Doxycycline | No dose information. 50 mg oral bid. | Reduced to qd after 4 weeks. | Placebo Minocycline | No dose information. 50 mg oral bid. | Reduced to qd after 4 weeks. | Continuous Discrete
| 311 | Doxycycline | 100 mg oral qhs. | 5% salicylic acid & 5% resorcinolin spir dit. Ket. Preparation applied twice a day. | Minocycline | 100 mg oral qhs. | 5% salicylic acid & 5% resorcinolin spir dit. Ket. Preparation applied twice a day. | Continuous Discrete
H.04.02 | 24 | Erythromycin | 500 mg oral bid. | Local treatment with Tioxolon^®^ (camyra powder 0.1%, bid). | Erythromycin | 500 mg oral bid. | Local treatment with Tioxolon^®^ (camyra powder 0.1 %, bid). | Continuous Discrete
H.04.03 | 6 | Erythromycin | 250 mg oral bid. | | Tetracycline | 250 mg oral bid. | | Discrete
| 36 | Erythromycin acistrate | 200 mg oral qd. | Week 1: 400 mg bid; week 2: 200 mg bid; following weeks: 200 mg qd. | Tetracycline | 250 mg oral qd. | Week 1: 500 mg bid; week 2: 250 mg bid; following weeks: 250 mg qd. | Continuous Discrete
| 125 | Placebo Erythromycin | No dose information. 500 mg oral qd. | Erythromycin tid for first 4 weeks; placebo bid for first first 4 weeks. Gently wash affected area twice daily with Purpose^®^. | Placebo Placebo Tetracycline | No dose information. No dose information. No dose information. | Tetracycline bid for first 4 weeks; placebo tid for 4 weeks. Gently wash affected area twice daily with Purpose^®®^soap. | Continuous Discrete
H.04.04 | 340 | Erythromycin proprionate | No dose information. | | Triacetyl-oleandomycin | No dose information. | | Discrete (M)
| | Erythromycinstearate | No dose information. | Dosage described as “3” doses daily for at least 60 days and after that they (pts) could adjust the dose as they felt they needed to do.”. Acne surgery done by the author; resorciline sulfur preparation once daily, usually at bedtime. | Triacetyl-oleandomycin | No dose information. | | Discrete (M)
H.04.05 | 4 | Roxithromycin | 150 mg oral qd. | | Roxithromycin | 300 mg oral qd. | | Discrete
H.04.06 | 247 | Oleandomycin | 250 mg oral qid. | | Triacetyl-oleandomycin | 250 mg oral qid. | | Discrete
H.05.01 | 161 | Minocycline | 100 mg oral qd. | 200 mg qd x1 week, then 100 mg qd x 4 weeks. | Placebo | No dose information. | Identical in appearance to minocycline. | Continuous Discrete
H.05.02 | 268 | Minocycline | 50 mg oral qd. | Simple soap twice daily. | Clindamycin | 1 % topical bid. | Simple soap twice daily. | Continuous Discrete
| 307 | Placebo Minocycline | No dose information. 50 mg oral bid. | Before meals. | Placebo Clindamycin phosphate | No dose information. 1 % topical bid. | Applied to entire face. | Continuous
H.05.04 | 72 | Minocycline | 50 mg oral bid. | | Tetracycline | 250 mg oral bid. | | Continuous Discrete
| 171 | Minocycline | 50 mg oral bid. | | Tetracycline hydrochloride | 250 mg oral bid.
| 298 | Minocycline | 50 mg oral bid. | | Tetracycline | 250 mp oral bid. | | Continuous Discrete
H.06.01 | 250 | Oxytetracycline | 125 mg oral qd. | Before meal; cross to placebo at 1 to 3 months. Standard program = hands off, soap and water 3x day, apply prescribed resocrinol and sulfur shake lotion at night, keep hair clean, take sun baths. | Placebo | No dose information. | Before meal; cross to oxytetracycline at 1 to 3 months. Standard program = hands off, soap and water 3x day, apply prescribed resocrinol and sulfur shake lotion at night, keep hair clean, take sun baths. | Discrete
H.06.02 | 255 | Oxytetracycline Vehicle | 250 mg oral bid. No dose information. | | Placebo Benzoyl peroxide | No dose information. 5 % topical qd. | | Continuous Discrete
H.06.03 | 123 | Vehicle Oxytetracycline | No dose information. 250 mg oral bid. | Tablets taken 30minutes before meals. | Placebo Metronidazole Benzoyl peroxide | No dose information. 2 % topical bid. 5 % topical bid. | | Discrete
H.06.045 | 40 | Tetracycline | 2.2 % topical bid. | 1.25mg/day n-decyl methyl sulphoxide. Oral tetracycline 1000mg/day 1st 4 weeks, 500 day next 4 weeks, out of 16 weeks total study duration. | Placebo | 70 ml topical bid. | Oral tetracycline-1000 mg/day 1st 4 weeks, 500 mg/day next 4 weeks out of 16 weeks total study duration. | Continuous Discrete
H.06.05 | 255 | Oxytetracycline Vehicle | 250 mg oral bid. No dose information. | | Placebo Tetracycline | No dose information. No dose information. | | Continuous Discrete
H.06.06 | 152 | Oxytetracycline | 250 mg oral bid. | | Sulphamethoxazole Trimethoprim | 400 mg oral bid. 80 mg oral bid. | | Continuous Discrete
H.06.07 | 128 | Oxytetracycline | 250 mg oral tid. | Tid for 4 weeks then bid. | Trimethoprim | 100 mg oral tid. | Tid for 4 weeks then bid. | Continuous Discrete
H.07.01 | 160 | Sulphamethoxazole Trimethoprim | 400 mg oral qd. 80 mg oral qd. | | Vehicle | No dose information. | | Continuous
| 223 | Cotrimoxazole | No dose information. | Strength of tablet not mentioned. Washing with soap. | Placebo | No dose information. | Washing with soap. | Continuous Discrete
H.07.02 | 41 | Sulfadimethoxine | 500 mg oral bid. | 1 g bid for 1 week; 0.5 g qd for 4 weeks. Cleaning soap and water; exposure to Westinghouse^®^ sun lamp acne lotion. | Placebo | No dose information. | | Discrete
H.08.01 | 10 | Tetracycline Vehicle | 250 mg oral bid. No dose information. | | Placebo Vehicle | 250 mg oral bid. No dose information. | | Continuous Discrete
H.08.01 | 23 | Tetracycline hydrochloride Placebo | 250 mg oral bid. No dose information. | | Placebo Placebo | No dose information. No dose information. | Non-antibacterial soap and shampoo. | Continuous
| 33 | Vehicle Tetracycline | No dose information. 250 mg oral bid. | | Vehicle Vehicle | No dose information. No dose information. | | Continuous Discrete
| 69 | Tetracycline | 250 mg oral bid. | Qid x 2 wks, then tid x 4 wks, then bid. | Topical treatment | No dose information. | Local treatment was one or combination of lotion, ointment or pastes and cryotherapy. Active ingredients were not mentioned. | Discrete
| 71 | Tetracycline hydrochloride | 250 mg oral qid. | | Vehicle | No dose information. | | Discrete
| 136 | Placebo Tetracycline hydrochloride | No dose information. 250 mg oral bid. | Placebo for clindamycin. Vehicle isopropyl alcohol+water. | Placebo solution Placebo capules | No dose information. No dose information. | Placebo solution vehicle isopropyl alcohol water. Placebo for tetracycline and for clindamycin. | Continuous Discrete
| 201 | Tetracycline | 250 mg oral bid. | | Placebo | No dose information. | | Continuous Discrete
| 313 | Placebo Tetracycline hydrochloride | No dose information. 250 mg oral bid. | Non-antibacterial soaps and shampoo. | Placebo Placebo | No dose information. No dose information. | Non-antibacterial soaps and shampoo. | Continuous
H.08.02 | 29 | Vehicle Tetracycline | No dose information. 250 mg oral bid. | Capsule taken on empty stomach every morning & evening, one hour before or 2 hours after meals. | Placebo Clindamycin phosphate | No dose information. 1 % topical bid. | Dabbed on skin every morning and night after washing. | Continuous
| 33 | Vehicle Tetracycline | No dose information. 250 mg oral bid. | | Vehicle Clindamycin | No dose information. No dose information. | Clindamycin pH adjusted. | Continuous Discrete
| 136 | Placebo Tetracycline hydrochloride | No dose information. 250 mg oral bid. | Placebo for clindamycin. Vehicle isopropyl alcohol+water. | Placebo Clindamycin phosphate | No dose information. 1 % topical bid. | Placebo for tetracycline. Vehicle isopropyl alcohol+water. | Continuous Discrete
| 186 | Tetracycline hydrochloride | 500 mg oral bid. | Placebo (topical) for 1st 3 weeks, 2x1day. For remainder of 9 weeks: 250mg (2 x day) + placebo (topical) (2x day). | Placebo Clindamycin | No dose information. 1 % topical bid. | 4 pts. Missed more than 1 follow-up visit; 5 had too many lesions; and, 7 had too few papules. | Continuous Discrete
H.08.02 | 318 | Placebo Tetracycline | No dose information. 250 mg oral bid. | Placebo for Clindamycin phosphate. | Clindamycin phosphate | No dose information. | Placebo for tetracycline.
H.08.03 | 279 | Placebo Tetracycline hydrochloride | No dose information. 250 mg oral bid. | | Placebo Erythromycin | No dose information. 1.5 % topical bid. | | Continuous Discrete
H.08.04 | 10 | Tetracycline Vehicle | 250 mg oral bid. No dose information. | | Placebo Tetracycline | 250 mg oral bid. 0.5 % topical bid. | | Continuous Discrete
| 23 | Tetracycline hydrochloride Placebo | 250 mg oral bid. No dose information. | | Placebo Tetracycline hydrochloride | No dose information. 0.5 % topical (can't 0.5 % topical (can't say) | Non-antibacterial soap and shampoo. | Continuous
| 313 | Placebo Tetracycline hydrochloride | No dose information. 250 mg oral bid. | Non-antibacterial soaps and shampoo. | Placebo Tetracycline hydrochloride | No dose information. 0.5 % topical bid. | 0.5% tetracycline = 0.22% tetracycline hcl + 0.28% 4-epi-tracycline HCl. Non-antibacterial soaps and shampoo. | Continuous
H.08.05 | 22 | Tetracycline | 250 mg oral qid. | | Azelaic acid | 20 % topical bid. | | Continuous Discrete
| 166 | Tetracycline hydrochloride | 500 mg oral (can't say) | 1000 mg/day for first month, 750 mg/day for second. | Placebo Placebo Azelaic acid | No dose information. No dose information. 20 % topical bid. | | Continuous Discrete
| 167 | Placebo Tetracycline hydrochloride | No dose information. 500 mg oral () | 1000 mg /day for first month, 750 mg/day for the second month, 500 mg/day for third month, then adjusted as needed. | Placebo Azelaic acid | No dose information. 20 % topical bid. | | Continuous Discrete
H.08.06 | 164 | Tetracycline Vehicle | 250 mg oral bid. No dose information. | The placebo cream is the vehicle base of meclosorb^®^. | Placebo Meclocycline sulfosalicylate | No dose information. 1 % topical bid. | | Continuous
H.08.08 | 212 | Tetracycline | 250 mg oral qd. | 1st month bid; 2nd qd; 3rd every other day. Usual cosmetics and soap. | Tetracycline hydrochloride | 250 mg oral bid. | 1st month bid; 2nd qd; 3rd every other day. Usual cosmetics and soap. | Discrete
| 317 | Proteolytic enzymes | 50000 units oral qid. | Enzymes: chymotropin/tryposin 1:6. | Tetracycline | 250 mg oral qid. | | Discrete
| | Tetracycline | 250 mg oral qid.
| | Tetracycline | 250 mg oral qid. | | Proteolytic enzymes Tetracycline | 50000 units oral qid. 250 mg oral qid. | Enzymes: chymotropin/tryposin 1:6. | Discrete
H.08.085 | 299 | Sodium novobiocin Tetracycline | 125 mg oral qid. 250 mg oral qid. | Tried for 2 weeks with 4 capsules a day then increase or decrease but ideal was 4/d. Non abrasive soap; 1% salicyclic acid in ethyl alcohol; sulfur-resorcin lotion. | Placebo | No dose information. | Non abrasive soap; 1% salicyclic acid in ethyl alcohol; sulfur-resorcin lotion.
H.08.14 | 236 | Tetracycline Povidone-iodine | 250 mg oral bid. No dose information. | Povidone-iodine is bid to tid. | Vehicle Tetracycline | No dose information. 250 mg oral bid. | | Discrete
H.09.01 | 293 | Dapsone | No dose information. | | Placebo | No dose information. | | Discrete
H.09.02 | 312 | Phenethicillin | 250 mg oral qid. | 1/2 hr. Before meals. | Placebo | No dose information. | 1/2 hour after meals. | Continuous Discrete
H.09.04 | 344 | Fusidin | 250 mg oral qd. | | Fusidin | 2 % topical bid. | | Discrete
H.09.05 | 340 | Tetracycline-novobiocin | No dose information. | | Placebo | No dose information. | | Discrete (M)

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table H2. CONTINUOUS outcomes for class ANTI-BACTERIAL (ORAL)

Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Target | | Comparator | | Between P-value
Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Data Type: Mean (SD) | Within P | Data Type: Mean (SD) | Within P | Between P-value
56 Parallel | N=98 Mod/sev | H.01.01 | Comedones change (%) | Short (6) | Clindamycin Percent change: −48 | | Vehicle Percent change: −22 | | 0.05
| | | Pustules change (%) | Short (6) | Percent change: −70 | | Percent change: −38 | | 0.01
| | | Comedones change (%) | Mid (10) | Percent change: −55 | | Percent change: −35 | | NS
| | | Pustules change (%) | Mid (10) | Percent change: −78 | | Percent change: −48 | | 0.01
| | | Comedones change (%) | Long (13) | Percent change: −48 | | Percent change: −22 | | 0.05
| | | Pustules change (%) | Long (13) | Percent change: −80 | | Percent change: −28 | | 0.01
265 ↑ Parallel | N=48 Mod | H.01.02 | Comedones (count) Baseline counts: 38 (Target)/36 (Comparator) | Short (4) | Clindamycin Percent Change*: −32 | | Tetracycline Percent Change*: −42
| | | Overall change/physician (rating) | Short (4) | Measure: 2 | | Measure: 2
| | | Pustules (count) Baseline counts: 27 (Target)/20 (Comparator) | Short (4) | Percent Change*: −56 | | Percent Change*: −75
| | | Severity (panzer) | Short (4) | Measure: 2 | | Measure: 1
| | | Comedones (count) Baseline counts: 38 (Target)/36 (Comparator) | Mid (8) | Percent Change*: −47 | | Percent Change*: −64
| | | Overall change/physician (rating) | Mid (8) | Measure: 2 | | Measure: 2
| | | Pustules (count) Baseline counts: 27 (Target)/20 (Comparator) | Mid (8) | Percent Change*: −67 | | Percent Change*: −90
| | | Severity (panzer) | Mid (8) | Measure: 2 | | Measure: 1
312 ↑ Parallel | N=66 Mild/mod/sev | H.02.01 | Overall change/patient (score) | Short (4) | Demethylchlortetracycline Measure: 4 (3.6) | | Placebo Measure: 3 (4.8) | | NS
312 ↑ Parallel | N=66 Mild/mod/sev | | Severity change/photo (score) Count location: Entire face. | Short (4) | Measure: 1 (2.5) | | Measure: 1 (2.4) | | NS
312 ↑ Parallel | N=66 Mild/mod/sev | H.02.02 | Overall change/patient (score) | Short (4) | Demethylchlortetracycline Measure: 4 (3.6) | | Phenethicillin Measure: 3 (4.8) | | NS
| | | Severity change/photo (score) Count location: Entire face. | Short (4) | Measure: 1 (2.5) | | Measure: 1 (3.1) | | NS
273 ↓ Cross-over | N=62 Mild | H.03.01 | Total inflammatory [phase i] (count) Baseline counts: 14 (Target)/13 (Comparator) | Short (4) | Doxycycline Percent Change*: −36 | .001 | Placebo Percent Change*: 12 | NS
| | | Total inflammatory [phase ii] (count) Baseline counts: 12 (Target)/12 (Comparator) | Short (4) | Percent Change*: −24 | .05 | Percent Change*: 02 | NS
1 ↑ Parallel | N=110 Mild/mod | H.03.02 | Total lesions (count) Count location: Half face. | Short (6) | Doxycycline Raw count: 4 (10.) | .001 | Fusidic acid cream Raw count: 5 (7.) | .001 | NS*
| | | Total lesions (count) | Mid (10) | Raw count: 4 (10.) | .001 | Raw count: 4 (7.) | .001 | NS*
25 ↑ Parallel | N=56 Mod | H.03.03 | Inflammatory change (%) Count location: Entire face. | Short (6) | Doxycycline + placebo Percent change: 16 | .001 | Erythromycin stearate + placebo Percent change: 15 | .001 | NS
| | | Severity (kligman) | Short (6) | Measure: 1 | | Measure: 1
311 Parallel | N=18 Mild/mod | H.03.04 | Severity change (smit) | Mid (12) | Doxycycline Measure: 22 (10.) | | Minocycline Measure: 23 (15.) | | NS
257 Parallel | N=79 Mod/sev | H.03.04 | Closed comedones (count) Baseline counts: 21 (Target)/18 (Comparator) | Short (4) | Doxycycline + placebo Percent Change*: −12 | | Minocycline + placebo Percent Change*: −17 | | NS*
257 Parallel | N=79 Mod/sev | | Open comedones (count) Baseline counts: 24 (Target)/24 (Comparator) | Short (4) | Percent Change*: −08 | | Percent Change*: −08 | | NS*
| | | Papules (count) Baseline counts: 31 (Target)/35 (Comparator) | Short (4) | Percent Change*: −45 | | Percent Change*: −37 | | NS*
| | | Pustules (count) Baseline counts: 13 (Target)/20 (Comparator) | Short (4) | Percent Change*: −46 | | Percent Change*: −50 | | NS*
| | | Total lesions (count) Baseline counts: 90 (Target)/98 (Comparator) | Short (4) | Percent Change*: −31 | | Percent Change*: −34 | | NS*
| | | Closed comedones (count) Baseline counts: 21 (Target)/18 (Comparator) | Mid (12) | Percent Change*: −41 | | Percent Change*: −44 | | NS*
| | | Open comedones (count) Baseline counts: 24 (Target)/24 (Comparator) | Mid (12) | Percent Change*: −38 | | Percent Change*: −29 | | NS*
| | | Papules (count) Baseline counts: 31 (Target)/35 (Comparator) | Mid (12) | Percent Change*: −61 | | Percent Change*: −67 | | NS*
| | | Pustules (count) Baseline counts: 13 (Target)/20 (Comparator) | Mid (12) | Percent Change*: −62 | | Percent Change*: −60 | | NS*
| | | Total lesions (count) Baseline counts: 90 (Target)/98 (Comparator) | Mid (12) | Percent Change*: −44 | | Percent Change*: −49 | | NS*
155 Parallel | N=43 Mild/mod/sev | H.03.04 | Cysts change (%) Count location: Neck anterior to sternomastoid muscles and face, e. | Mid (12) | Doxycyline Percent change: −89 | | Minocyline Percent change: −81 | | NS
| | | Nodules change (%) | Mid (12) | Percent change: −73 | | Percent change: −72 | | NS
| | | Papules changes (%) | Mid (12) | Percent change: −67 | | Percent change: −67 | | NS
155 Parallel | N=43 Mild/mod/sev | | Pustules change (%) Count location: Neck anterior to sternomastoid muscles and face, e. | Mid (12) | Percent change: −84 | | Percent change: −82 | | NS
| | | Severity change (% Wright) | Mid (12) | Measure: −66 | | Measure: −68 | | NS
| | | Total lesions (%) | Mid (12) | Percent change: −59 | | Percent change: −59 | | NS
24 ↑ Parallel | N=40 Mod | H.04.02 | Papules (count) Count location: Face. | Short (2) | Erythromycin (stearate) Raw count: 13 (7.21) | .001 | Erythromycin (base) Raw count: 21 (9.6) | .001 | 0.01
125 ↑ Parallel | N=178 Mild/mod | H.04.03 | Closed comedones change (%) | Short (4) | Erythromycin + placebo Percent change: −7 | | Tetracycline + placebo Percent change: −24 | | 0.05
| | | Papules change (%) | Short (4) | Percent change: −39 | | Percent change: −34 | | NS
| | | Pustules change (%) | Short (4) | Percent change: −57 | | Percent change: −50 | | NS
| | | Closed comedones change (%) | Mid (12) | Percent change: −17 | | Percent change: −36 | | NS
| | | Open comedones change (%) | Mid (12) | Percent change: −26 | | Percent change: −31 | | NS
| | | Papules change (%) | Mid (12) | Percent change: −60 | | Percent change: −62 | | NS
| | | Pustules change (%) | Mid (12) | Percent change: −73 | | Percent change: −65 | | NS
36 ↑ Parallel | N=60 Mod/sev | H.04.03 | Back severity (harcup/median) Count location: Back. | Mid (12) | Erythromycin acistrate Measure: 2 | .05 | Tetracycline Measure: 2 | .05 | NS
| | | Chest severity (harcup/median) Count location: Chest. | Mid (12) | Measure: 2 | .05 | Measure: 1 | .05 | NS
| | | Face/neck severity (harcup/median) Count location: Face/neck. | Mid (12) | Measure: 2 | | Measure: 1 | .05
| | | Back severity (harcup/median) Count location: Back. | Long (24) | Measure: 2 | .05 | Measure: 2 | .05 | NS
| | | Chest severity (harcup/median) Count location: Chest. | Long (24) | Measure: 1 | .05 | Measure: 1 | .05 | NS
| | | Face/neck severity (harcup/median) Count location: Face/neck. | Long (24) | Measure: 1 | .05 | Measure: 1 | .05 | NS
161 ↑ Cross-over | N=43 | H.05.01 | Severity (witkowski) | Short (5) | Minocycline Measure: −40 | .05 | Placebo Measure: −16 | NS
| | | Severity change [phase ii] (group %) | Short (5) | Measure: −43 | .05 | Measure: −24 | NS
268 ↑ Parallel | N=80 Mod/sev | H.05.02 | Inflammatory (count) Count location: Face + or − other. Baseline counts: 80 (Target)/80 (Comparator) | Short (4) | Minocycline Percent Change*: −23 | | Clindamycin Percent Change*: −30 | | NS*
| | | Non-inflammatory (count) Count location: Face + or − other. Baseline counts: 62 (Target)/60 (Comparator) | Short (4) | Percent Change*: −27 | | Percent Change*: −25 | | NS*
| | | Overall assessment (vas) Count location: Face + or − other. | Short (4) | Measure: 27 (20.) | | Measure: 29 (20.) | | NS
| | | Inflammatory (count) Count location: Face + or − other. Baseline counts: 80 (Target)/80 (Comparator) | Mid (12) | Percent Change*: −44 | .0001 | Percent Change*: −31 | .0001 | NS
| | | Non-inflammatory (count) Count location: Face + or − other. Baseline counts: 62 (Target)/60 (Comparator) | Mid (12) | Percent Change*: −40 | .0002 | Percent Change*: −33 | .0002 | NS
| | | Overall assessment (vas) Count location: Face + or − other. | Mid (12) | Measure: 15 (10.) | .0001 | Measure: 18 (20.) | .0001 | NS
307 ↑ Parallel | N=64 Mod/sev | H.05.02 | Inflammatory (count) | Short (4) | Minocycline + placebo Raw count: 38 (5.) | | Clindamycin phosphate + placebo Raw count: 35 (5.) | | #Error
| | | Non-inflammatory (count) Count location: Face. | Short (4) | Raw count: 51 (4.1) | NS | Raw count: 46 (4.) | NS | NS
| | | Severity (leeds) | Short (4) | Measure: 1 (0.6) | | Measure: 1 (0.5) | | NS
171 Cross-over | N=104 Mod/sev | H.05.04 | Severity reduction (cumulative %) | Short (6) | Minocycline Measure: 52 | | Tetracycline Measure: 28 | | NS
298 ↑ Parallel | N=62 Mod/sev | | Severity/investigator (samuelson) | Short (6) | Measure: 4 (2.3) | | Measure: 4 (1.66) | | NS
| | | Severity/patient (samuleson) | Short (6) | Measure: 4 (2.2) | | Measure: 4 (1.55) | | NS
171 Cross-over | N=104 Mod/sev | | Severity reduction (cumulative %) | Mid (12) | Measure: 75 | | Measure: 70 | | NS
298 ↑ Parallel | N=62 Mod/sev | | Severity/investigator (samuelson) | Mid (12) | Measure: 3 (1.99) | | Measure: 3 (2.2) | | NS
| | | Severity/patient (samuelson) | Mid (12) | Measure: 3 (1.9) | | Measure: 3 (1.98) | | NS
72 | N=100 | | Comedones (count) Count location: Right. Baseline counts: 35 (Target)/30 (Comparator) | Long (19) | Percent Change*: −42 | | Percent Change*: −36
| | | Cysts (count) Count location: Right. Baseline counts: 1 (Target)/1 (Comparator) | Long (19) | Percent Change*: −62 | | Percent Change*: −57
| | | Papules (count) Count location: Right. Baseline counts: 16 (Target)/11 (Comparator) | Long (19) | Percent Change*: −48 | | Percent Change*: −41
| | | Pustules (count) Count location: Right. Baseline counts: 9 (Target)/14 (Comparator) | Long (19) | Percent Change*: −60 | | Percent Change*: −72
171 Cross-over | N=104 Mod/sev | | Severity reduction (cumulative %) | Long (24) | Measure: 100 | | Measure: 100 | | NS
| | | Time to severity reduction (days) | Long (24) | Measure: 63 | | Measure: 78 | | NS
H.06.02 | | | | Oxytetracycline (oral) + vehicle | | | Benzoyl peroxide + placebo (oral)
255 Parallel | N=69 Mod | | Back severity (leeds) Count location: Back. | Mid (12) | Measure: 0 (0.19) | .02 | Measure: 0 (0.41) | NS | NS
| | | Chest severity (leeds) Count location: Chest. | Mid (12) | Measure: 0 (0.13) | NS | Measure: 0 (0.4) | NS | NS
| | | Face severity (leeds) Count location: Face. | Mid (12) | Measure: 0 | .001 | Measure: 1 | .001 | NS
255 Parallel | N=69 Mod | | Inflammatory (count) Baseline counts: 62 (Target)/57 (Comparator) | Mid (12) | Percent Change*: −23 | NS | Percent Change*: −42 | .001 | NS
| | | Non-inflammatory (count) Count location: Face. | Mid (12) | Raw count: 61 | .02 | Raw count: 31 | .001 | NS
H.06.05 | | | | Oxytetracycline (oral) + vehicle | | | Tetracycline (topical) + placebo (oral)
255 Parallel | N=69 Mod | | Back severity (leeds) Count location: Back. | Mid (12) | Measure: 0 (0.19) | .02 | Measure: 0 (0.47) | NS | NS
| | | Chest severity (leeds) Count location: Chest. | Mid (12) | Measure: 0 (0.13) | NS | Measure: 0 (0.26) | NS | NS
| | | Face severity (leeds) Count location: Face. | Mid (12) | Measure: 0 | .001 | Measure: 0 | .01 | NS
| | | Inflammatory (count) Baseline counts: 62 (Target)/65 (Comparator) | Mid (12) | Percent Change*: −23 | NS | Percent Change*: −35 | .02 | NS
| | | Non-inflammatory (count) Count location: Face. | Mid (12) | Raw count: 61 | .02 | Raw count: 43 | .003 | NS
152 ↑ Parallel | N=16 Mild/mod/sev | H.06.06 | Severity (leeds) Count location: Entire face chest & back. | Mid (12) | Oxytetracycline Measure: 4 (2.6) | | Trimethoprim + sulfamethoxazole Measure: 3 (3.3) | | NS
128 ↑ Parallel | N=45 Mild | H.06.07 | Active papules (sqrt count) Count location: Face (unspecified). | Short (4) | Oxytetracycline Percent Change*: −38 | .01 | Trimethoprim Percent Change*: −46 | .01 | NS
| | | Active pustules (sqrt count) Count location: Face (unspecified). | Short (4) | Percent Change*: −49 | .01 | Percent Change*: −15 | .01 | NS
| | | Back severity (log leeds) Count location: Back. | Short (4) | Measure: 0 (0.08) | .01 | Measure: 0 (0.08) | .01 | NS
| | | Chest severity (log leeds) Count location: Chest. | Short (4) | Measure: 0 (0.08) | .01 | Measure: 0 (0.08) | .01 | NS
128 ↑ Parallel | N=45 Mild | | Face severity (log leeds) Count location: Face (unspecified). | Short (4) | Measure: 0 (0.08) | .01 | Measure: 0 (0.08) | .01 | NS
| | | Less active papules (sqrt count) | Short (4) | Percent Change*: −26 | .01 | Percent Change*: −13 | .01 | NS
| | | Less active pustules (sqrt count) Count location: Face (unspecified. | Short (4) | Percent Change*: −30 | .01 | Percent Change*: −35 | .01 | NS
| | | Active papules (sqrt count) Count location: Face (unspecified). | Mid (8) | Percent Change*: −47 | .01 | Percent Change*: −61 | .01 | NS
| | | Active pustules (sqrt count) | Mid (8) | Percent Change*: −72 | .01 | Percent Change*: −63 | .01 | NS
| | | Back severity (log leeds) Count location: Back. | Mid (8) | Measure: 0 (0.08) | .01 | Measure: 0 (0.08) | .01 | NS
| | | Chest severity (log leeds) Count location: Chest. | Mid (8) | Measure: 0 (0.08) | .01 | Measure: 0 (0.08) | .01 | NS
| | | Face severity (log leeds) Count location: Face (unspecified). | Mid (8) | Measure: 0 (0.08) | .01 | Measure: 0 (0.08) | .01 | NS
| | | Less active papules (sqrt count) | Mid (8) | Percent Change*: −36 | .01 | Percent Change*: −27 | .01 | NS
| | | Less active pustules (sqrt count) Count location: Face (unspecified). | Mid (8) | Percent Change*: −26 | .01 | Percent Change*: −24 | .01 | NS
160 ↑ Cross-over | N=42 | H.07.01 | Severity change (witkowski %) [phase 1] | Short (5) | Trimethoprim + sulpamethoxazole Measure: −62 | .001 | Vehicle Measure: −9 | NS
| | | Severity change [phase 2] (witkowski %) | Short (5) | Measure: −43 | .001 | Measure: 35 | NS
23 ↑ Parallel | N=75 Mod | H.08.01 | Severity change (cook) Count location: Entire face-(photos). | Short (6) | Placebo (topical) + tetracycline hydrochloride (oral) Measure: −1 (1.1) | | Placebo (topical) + placebo (oral) Measure: 0 (1.) | | 0.05
| | | Severity change (cook) | Long (13) | Measure: −2 (1.2) | | Measure: −1 (1.2) | | 0.05
201 ↑ Parallel | N=51 | H.08.01 | Severity change (pillsbury modified) | Short (6) | Tetracycline Measure: −1 (0.3) | | Placebo Measure: 0 (0.3) | | 0.001
201 ↑ Parallel | N=51 | | Severity change (pillsbury modified) | Mid (12) | Measure: −2 (0.3) | | Measure: 0 (0.3) | | 0.001
H.08.01 | | | | Tetracycline (oral) + vehicle (topical) | | | Vehicle (topical) + placebo (oral)
10 Parallel | N=60 Mod | | Severity (anderson) Count location: Butterfly. | Short (6) | Measure: 4 | NS | Measure: 4 | NS | NS
136 Parallel | N=305 Mod/sev | H.08.01 | Papules (count) Count location: Face above jawline. Between P-value: T > P. Baseline counts: 22 (Target)/11 (Comparator) | Short (6) | Tetracycline + Placebo Percent Change*: −59 | | Placebo Percent Change*: 24 | | 0.05
| | | Pustules (count) Count location: Face above jawline. Baseline counts: 5 (Target)/4 (Comparator) | Short (6) | Percent Change*: −60 | | Percent Change*: −40 | | NS
| | | Papules (count) Count location: Face above jawline. Between P-value: T > P. Baseline counts: 22 (Target)/11 (Comparator) | Mid (8) | Percent Change*: −63 | | Percent Change*: 07 | | 0.05
| | | Pustules (count) Count location: Face above jawline. Between P-value: T > P. Baseline counts: 5 (Target)/4 (Comparator) | Mid (8) | Percent Change*: −68 | | Percent Change*: −37 | | 0.05
33 Parallel | N=87 Mild | H.08.01 | Inflammatory (count) Baseline counts: 6 (Target)/7 (Comparator) | Short (6) | Tetracycline + vehicle Percent Change*: −51 | .0001 | Vehicle (oral) + vehicle (topical) Percent Change*: −12 | | NS*
| | | Inflammatory (count) Between P-value: compared to clinda. Baseline counts: 6 (Target)/7 (Comparator) | Mid (8) | Percent Change*: −57 | .0001 | Percent Change*: −12 | NS | 0.0004
313 ↑ Parallel | N=149 Mild/mod | H.08.01 | Severity (cook) Count location: Face. Between P-value: with respect to topical. | Short (4) | Tetracycline hydrochloride (oral) + placebo Measure: 3 | .05 | Placebo + placebo Measure: 4 | NS | NS
313 ↑ Parallel | N=149 Mild/mod | | Severity (cook) Count location: Face. Between P-value: with respect to topical. | Mid (12) | Measure: 2 | .05 | Measure: 3 | NS | NS
318 Parallel | N=50 Mod | H.08.02 | Overall change/patient (stoughton) | Short (6) | Tetracycline (oral) + Placebo (lotion) Measure: 2 | | Clindamycin (lotion) + Placebo (oral) Measure: 2 | | 0.014
| | | Papules (count) Count location: Face unspecified. Baseline counts: 18 (Target)/17 (Comparator) | Short (6) | Percent Change*: −36 | | Percent Change*: −67 | | 0.01
136 Parallel | N=305 Mod/sev | H.08.02 | Papules (count) Count location: Face above jawline. Between P-value: T > P. Baseline counts: 22 (Target)/23 (Comparator) | Short (6) | Tetracycline + Placebo Percent Change*: −59 | | Clindamycin + Placebo Percent Change*: −62 | | 0.05
| | | Pustules (count) Count location: Face above jawline. Baseline counts: 5 (Target)/5 (Comparator) | Short (6) | Percent Change*: −60 | | Percent Change*: −67 | | NS
| | | Papules (count) Count location: Face above jawline. Between P-value: T > P. Baseline counts: 22 (Target)/23 (Comparator) | Mid (8) | Percent Change*: −63 | | Percent Change*: −68 | | 0.05
| | | Pustules (count) Count location: Face above jawline. Between P-value: T > P. Baseline counts: 5 (Target)/5 (Comparator) | Mid (8) | Percent Change*: −68 | | Percent Change*: −76 | | 0.05
33 Parallel | N=87 Mild | H.08.02 | Inflammatory (count) Baseline counts: 6 (Target)/9 (Comparator) | Short (6) | Tetracycline + vehicle Percent Change*: −51 | .0001 | Clindamycin + vehicle Percent Change*: −68 | .0001 | NS*
| | | Inflammatory (count) Between P-value: compared to clinda. Baseline counts: 6 (Target)/9 (Comparator) | Mid (8) | Percent Change*: −57 | .0001 | Percent Change*: −72 | .0001 | 0.0004
29 ↑ Parallel | N=20 Mod | H.08.02 | Nodules (count) Count location: Entire face. Baseline counts: 1 (Target)/1 (Comparator) | Short (4) | Tetracycline + vehicle Percent Change*: −22 | | Clindamycin phosphate + placebo Percent Change*: −58 | | NS*
| | | Papules (count) Count location: Entire face. Baseline counts: 27 (Target)/21 (Comparator) | Short (4) | Percent Change*: −51 | | Percent Change*: −39 | | NS*
| | | Pustules (count) Count location: Entire face. Baseline counts: 7 (Target)/5 (Comparator) | Short (4) | Percent Change*: −66 | | Percent Change*: −22 | | NS*
| | | Nodules (count) Count location: Entire face. Baseline counts: 1 (Target)/1 (Comparator) | Mid (8) | Percent Change*: −78 | | Percent Change*: −67 | | NS*
| | | Papules (count) Count location: Entire face. Baseline counts: 27 (Target)/21 (Comparator) | Mid (8) | Percent Change*: −76 | | Percent Change*: −70 | | NS*
| | | Pustules (count) Count location: Entire face. Baseline counts: 7 (Target)/5 (Comparator) | Mid (8) | Percent Change*: −69 | | Percent Change*: −70 | | NS*
186 ↓ Parallel | N=44 Mod | H.08.02 | Closed comedones (count) | Short (6) | Tetracycline hydrochloride + placebo Raw count: 4 (4.) | | Clindamycin + placebo Raw count: 6 (14.) | | NS*
| | | Nodules (count) | Short (6) | Raw count: 1 (0.3) | | Raw count: 1 (2.) | | NS*
| | | Open comedones (count) | Short (6) | Raw count: 5 (4.) | | Raw count: 7 (18.) | | NS*
| | | Papules (count) | Short (6) | Raw count: 6 (4.) | | Raw count: 7 (9.) | | NS*
| | | Pustules (count) | Short (6) | Raw count: 6 (4.) | | Raw count: 7 (8.) | | NS*
| | | Closed comedones (count) | Mid (12) | Raw count: 3 (4.) | | Raw count: 3 (8.) | | NS*
| | | Nodules (count) | Mid (12) | Raw count: 0 (0.2) | | Raw count: 1 (0.8) | | NS*
| | | Open comedones (count) | Mid (12) | Raw count: 4 (4.) | | Raw count: 4 (8.) | | NS*
| | | Pustules (count) | Mid (12) | Raw count: 4 (4.) | | Raw count: 2 (4.) | | NS*
H.08.03 | | | | Tetracycline hydrochloride + placebo (topical) | | | Erythromycin + placebo (oral)
279 ↑ Parallel | N=54 Mod/sev | | Closed comedones change (count) Baseline counts: 26 (Target)/22 (Comparator) | Short (4) | Percent change*: −16 | NS | Percent change*: −31 | .05 | NS
| | | Comedones change (count) Baseline counts: 26 (Target)/26 (Comparator) | Short (4) | Percent change*: −29 | NS | Percent change*: −34 | .01 | NS
| | | Inflammatory change (count) Baseline counts: 30 (Target)/32 (Comparator) | Short (4) | Percent change*: −59 | .001 | Percent change*: −66 | .001 | NS*
| | | Open comedone change (count) Baseline counts: 13 (Target)/5 (Comparator) | Short (4) | Percent change*: −27 | NS | Percent change*: −47 | NS | NS
| | | Papules change (count) Baseline counts: 24 (Target)/26 (Comparator) | Short (4) | Percent change*: −57 | .001 | Percent change*: −66 | .001 | NS*
| | | Pustules change (count) Baseline counts: 6 (Target)/6 (Comparator) | Short (4) | Percent change*: −66 | .01 | Percent change*: −62 | .001 | NS*
| | | Closed comedone change (count) Baseline counts: 26 (Target)/22 (Comparator) | Mid (12) | Percent change*: −31 | .05 | Percent change*: −48 | .001 | NS
| | | Comedones change (count) Baseline counts: 26 (Target)/26 (Comparator) | Mid (12) | Percent change*: −58 | .05 | Percent change*: −51 | .001 | NS
| | | Inflammatory change (count) Baseline counts: 30 (Target)/32 (Comparator) | Mid (12) | Percent change*: −45 | .001 | Percent change*: −65 | .001 | NS*
| | | Open comedone change (count) Baseline counts: 13 (Target)/5 (Comparator) | Mid (12) | Percent change*: −56 | NS | Percent change*: −67 | .01 | NS
| | | Papules change (count) Baseline counts: 24 (Target)/26 (Comparator) | Mid (12) | Percent change*: −42 | .001 | Percent change*: −63 | .001 | NS*
279 ↑ Parallel | N=54 Mod/sev | | Pustules change (count) Baseline counts: 6 (Target)/6 (Comparator) | Mid (12) | Percent change*: −55 | .01 | Percent change*: −70 | .01 | NS*
23 ↑ Parallel | N=75 Mod | H.08.04 | Severity change (cook) Count location: Entire face-(photos). | Short (6) | Placebo (topical) + tetracycline hydrochloride (oral) Measure: −1 (1.1) | | Tetracycline hydrochloride (topical) + placebo (oral) Measure: −1 (0.85) | | 0.05
| | | Severity change (cook) | Long (13) | Measure: −2 (1.2) | | Measure: −1 (1.4) | | 0.05
H.08.04 | | | | Tetracycline (oral) + vehicle (topical) | | | Tetracycline (topical) + placebo (oral)
10 Parallel | N=60 Mod | | Severity (anderson) Count location: Butterfly. | Short (6) | Measure: 4 | NS | Measure: 3 | NS | NS
313 ↑ Parallel | N=149 Mild/mod | H.08.04 | Severity (cook) Count location: Face. Between P-value: with respect to topical. | Short (4) | Tetracycline hydrochloride (oral) + placebo Measure: 3 | .05 | Tetracycline hydrochloride (oral) + placebo Measure: 3 | .05 | NS
| | | Severity (cook) | Mid (12) | Measure: 2 | .05 | Measure: 2 | .05 | NS
22 ↓ Parallel | N=45 Mod/sev | H.08.05 | Face severity (leeds) | Short (4) | Tetracycline + placebo Measure: 1 | | Azelaic acid + placebo Measure: 2 | | NS
| | | Non-inflammatory (count) | Short (4) | Raw count: 41 | | Raw count: 44 | | NS
| | | Total inflammatory (count) Baseline counts: 43 (Target)/44 (Comparator) | Short (4) | Percent Change*: −35 | | Percent Change*: −14 | | NS
| | | Total lesions (count) Baseline counts: 130 (Target)/128 (Comparator) | Short (4) | Percent Change*: −28 | | Percent Change*: −16 | | NS
| | | Total severity (leeds) | Short (4) | Measure: 2 | | Measure: 4 | | NS
| | | Face severity (leeds) | Mid (8) | Measure: 1 | NS | Measure: 1 | NS | NS
| | | Non-inflammatory (count/median) | Mid (8) | Measure: 30 | sig | Measure: 42 | sig | NS
22 ↓ Parallel | N=45 Mod/sev | | Total inflammatory (count) Baseline counts: 43 (Target)/44 (Comparator) | Mid (8) | Percent Change*: −49 | sig | Percent Change*: −32 | sig | NS
| | | Total lesions (count/median) | Mid (8) | Measure: 90 | | Measure: 88 | | NS
| | | Total severity (leeds) | Mid (8) | Measure: 1 | sig | Measure: 4 | NS | NS
| | | Face severity (leeds) | Long (24) | Measure: 0 | | Measure: 1 | | NS
| | | Inflammatory (count) | Long (24) | Raw count: 12 | | Raw count: 28 | | NS
| | | Non-inflammatory (count) | Long (24) | Raw count: 22 | | Raw count: 28 | | NS
| | | Total lesions (count) Baseline counts: 130 (Target)/128 (Comparator) | Long (24) | Percent Change*: −54 | | Percent Change*: −41 | | 0.05
| | | Total severity (leeds) | Long (24) | Measure: 1 | .001 | Measure: 2 | .01 | 0.05
166 ↑ Parallel | N=333 Mild/mod | H.08.05 | Total lesions (count/median) | Long (20) | Tetracycline hydrochloride Measure: 5 | sig | Azelaic acid + placebo Measure: 6 | sig | NS
167 ↑ Parallel | N=261 Mod/sev | H.08.05 | Nodes+cysts (count/median) Count location: Half face. | Mid (12) | Tetracycline hydrochloride + placebo Measure: 5 | | Azelaic acid + placebo Measure: 6 | | NS
| | | Inflammatory (count/median) | Long (24) | Measure: 3 | | Measure: 2 | | NS
| | | Nodes+cysts (count/median) | Long (24) | Measure: 3 | | Measure: 2 | | NS
164 ↑ Parallel | N=60 Mild/mod | H.08.06 | Closed comedones change (%) | Short (4) | Tetracycline + vehicle Percent change: −70 | | Meclocycline sulfosalicylate + placebo Percent change: −36 | | NS
| | | Cysts change (%) | Short (4) | Percent change: −80 | | Percent change: −76 | | NS
| | | Open comedones change (%) | Short (4) | Percent change: −29 | | Percent change: 62 | | 0.02
| | | Papules change (%) | Short (4) | Percent change: −64 | | Percent change: −28 | | NS
| | | Pustules change (%) | Short (4) | Percent change: −57 | | Percent change: −41 | | NS
| | | Total lesions change (%) | Short (4) | Percent change: −67 | | Percent change: −49 | | NS
164 ↑ Parallel | N=60 Mild/mod | | Closed comedones change (%) | Mid (8) | Percent change: −83 | | Percent change: −60 | | NS
| | | Cysts change (%) | Mid (8) | Percent change: −85 | | Percent change: −92 | | NS
| | | Open comedones change (%) | Mid (8) | Percent change: −74 | | Percent change: 21 | | 0.04
| | | Papules change (%) | Mid (8) | Percent change: −63 | | Percent change: −77 | | NS
| | | Pustules change (%) | Mid (8) | Percent change: −80 | | Percent change: −63 | | NS
| | | Total lesions change (%) | Mid (8) | Percent change: −77 | | Percent change: −76 | | NS
312 ↑ Parallel | N=66 Mild/mod/sev | H.09.02 | Overall change/patient (score) | Short (4) | Phenethicillin Measure: 3 (4.8) | | Placebo Measure: 3 (4.8) | | NS
| | | Severity change/photo (score) Count location: Entire face. | Short (4) | Measure: 1 (3.1) | | Measure: 1 (2.4) | | NS

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., - our assessment of entry severity of study patients. “P”- parallel study, “S”- split face design. TARGET and COMPARATOR: “Percent change”- an outcome derived from individual final and baseline measures; “Percent change*”- we calculated a group-based percentage change; “Change” - raw difference from baseline; “Change*” - calculated change; “Measure” - an outcome measure with no baseline comparison. SD: standard deviation. WITHIN P: P-value with respect to baseline in one arm. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table H3: DISCRETE outcomes for class ANTI-BACTERIAL (ORAL)

Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Treatment | Comparator | Between P-value
Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Attribute: Number of patients | Attribute: Number of patients | Between P-value
56 Parallel Mod/sev N=98 | H.01.01 | Side effects | Long (13) | Clindamycin Severe diarrhea (withdraw) 1 Mild diarrhea 8 Stomach gas 1 Stomach ache (mild) 0 | Vehicle Severe diarrhea (withdraw) 0 Mild diarrhea 1 Stomach gas 0 Stomach ache (mild) 1
| | | | Heartburn (mild) 1 Urinary frequency (mild) 0 morbilliform rash (withdraw) 1 | Heartburn (mild) 0 Urinary frequency (mild) 1 Morbilliform rash (withdraw) 0
265 ↑ Parallel N=48 | H.01.02 | Esophagitis | Mid (8) | Clindamycin Present 1 Mod Absent 24 | Tetracycline Present 0 Absent 23
| | Mild diarrhea and cramping | Mid (8) | Present 1 Absent 24 | Present 0 Absent 23
| | Overall change/physician | Mid (8) | Much improved 13 Improved 9 Same 3 Worse 0 | Much improved 16 Improved 6 Same 1 Worse 0
275 ↓ Parallel Sev N=47 | H.01.02 | Overall change/patient (vas) | Mid (10) | Clindamycin hydrochloride Worse 0 Same 1 Improved 12 Much improved 1 | Tetracycline hydrochloride Worse 0 Same 1 Improved 13 Much improved 2
| | Diarrhea | Mid (11) | Withdraw 2 | Withdraw 0
| | Lesions change | Mid (11) | 25% or less decrease 2 More than 25% decrease 12 | 25% or less decrease 2 More than 25% decrease 14
162 ↑ Parallel Mod/sev N=37 | H.02.01 | Adverse effects | Mid (9) | Demethylchlortetracycline Photosensitivity 11 GI disturbance 2 Photo-onycholysis 2 | Placebo Photosensitivity 0 GI disturbance 0 Photo-onycholysis 0 | 0.01
162 ↑ Parallel Mod/sev N=37 | | Severity change | Mid (9) | Excellent or good 16 Poor 5 | Excellent or good 5 Poor 11 | 0.01
192 Parallel N=74 | | Overall change/physician | Short (3) | Good 29 Fair 3 Poor 5 Questionable 3 | Good 23 Fair 5 Poor 3 Questionable 3 | NS
193 Cross-over N=74 | | Overall change/physician, patient | Short (3) | Declo preferred 20 Placebo preferred 6 Equally good 7 Neither good 3 | Declo preferred 20 Placebo preferred 6 Equally good 7 Neither good 3 | 0.01
312 ↑ Parallel Mild/mod/sev N=66 | | Overall change/physician | Short (4) | Questionable 1 Improved 5 No change 10 Worse 0 Not assessed 3 | Questionable 1 Improved 3 No change 13 Worse 0 Not assessed 6 | NS
71 Cross-over N=150 | H.02.01 | Severity change | Short (4) | Demethylchlortetracycline Worse 8 No change after good response 3 No change 5 Slight 11 | Vehicle Worse 10 No change after good response 2 No change 9 Slight 11 | NS
| | Side effects | Short (4) | Good 4 Excellent 11 Photoreactivity 15 | Good 7 Excellent 3 Photoreactivity 1
312 ↑ Parallel Mild/mod/sev N=66 | H.02.02 | Overall change/physician | Short (4) | Demethylchlortetracycline Improved 5 No change 10 Worse 0 Not assessed 3 | Phenethicillin Improved 5 No change 10 Worse 1 Not assessed 4 | NS
71 Cross-over N=150 | H.02.03 | Severity change | Short (4) | Demethylchlortetracycline Worse 8 No change after good response 3 No change 5 Slight 11 | Tetracycline hydrochloride Worse 10 No change after good response 3 No change 6 Slight 15 | NS
| | Side effects | Short (4) | Good 4 Excellent 11 Photoreactivity 15 | Good 4 Excellent 3 Photoreactivity 3
70 ↑ Parallel N=100 | H.02.03 | Overall change/physician | Long (13) | Demethylchortetracycline Poor 0 Fair 1 Good 21 Excellent 12 | Tetracycline Poor 0 Fair 3 Good 28 Excellent 19 | 0.01
| | Side effects | Long (13) | Diarrhea 0 Nausea 0 Pruritus ani 0 | Diarrhea 4 Nausea 1 Pruritus ani 1 | 0.05
| | Relapse | Long (15) | Relapse 0 | Relapse 8
273 ↓ Cross-over Mild N=62 | H.03.01 | Comedones (discretized %) | Short (4) | Doxycycline Poor 47 Better than poor 15 | Placebo Poor 47 Better than poor 15
| | Cysts | Short (4) | Good/excellent 16 Fair/poor/worse 46 | Good/excellent 11 Fair/poor/worse 51
| | Inflammatory (discretized %) | Short (4) | Excellent 8 Good 13 Fair 7 Poor 20 | Excellent 4 Good 11 Fair 5 Poor 21
| | Papules change | Short (4) | Worse 14 Good/excellent 26 Fair/poor/worse 36 | Worse 21 Good/excellent 12 Fair/poor/worse 50
| | Pustules | Short (4) | Good/excellent 25 Fair/poor/worse 37 | Good/excellent 15 Fair/poor/worse 47
273 ↓ Cross-over Mild N=62 | | Side effects | Short (4) | Diarrhea 0 Nausea 0 Photoxicity 0 | Diarrhea 0 Nausea 0 Photoxicity 0
1 ↑ Parallel Mild/mod N=110 | H.03.02 | Overall change/investigator | Mid (10) | Doxycycline Cured 14 Improved 19 No effect 14 | Fusidic acid cream Cured 18 Improved 29 No effect 9
| | Overall change/patient | Mid (10) | Cured 14 Improved 19 No effect 14 | Cured 16 Improved 30 No effect 10 | NS
| | Side effects | Mid (10) | Unpleasant smell 0 Smarting of eyes 0 Discontinued due to nausea 1 None 46 | Unpleasant smell 2 Smarting of eyes 2 Discontinued due to nausea 0 None 52
311 Parallel Mild/mod N=18 | H.03.04 | Side effects | Mid (12) | Doxycycline GI pain/nausea 2 Constipation 1 Tired 1 None 4 | Minocycline GI pain/nausea 0 Constipation 0 Tired 0 None 8
257 Parallel Mod/sev N=79 | H.03.04 | Withdrawal due to side effects | Mid (12) | Doxycycline + placebo Dyspepsia 1 Headache 1 Nausea 0 Vertigo 0 | Minocycline + placebo Dyspepsia 1 Headache 0 Nausea 1 Vertigo 1
6 ↑ Parallel N=40 | H.04.03 | Severity change | | Erythromycin Very good 10 Good 3 Moderate 4 Poor 3 | Tetracycline Very good 8 Good 10 Moderate 1 Poor 1
6 ↑ Parallel N=40 | | Side effects | | Diarrhea 0 Nausea 1 Pruritus ani 0 Vomiting 1 | Diarrhea 1 Nausea 1 Pruritus ani 1 Vomiting 0
125 ↑ Parallel Mild/mod N=178 | H.04.03 | Side effects | | Erythromycin + placebo Side effects leading to withdrawal 7 GI distress 4 Vaginal candidiasis 0 Pseudotumor cerebri 1 | Tetracycline + placebo Side effects leading to withdrawal 2 GI distress 4 Vaginal candidiasis 1 Pseudotumor cerebri 1
| | Overall change/patient | Mid (12) | Rash 1 Improved or markedly improved 77 Worse or unchanged 23 | Rash 0 Improved or markedly improved 89 Worse or unchanged 11 | NS
36 ↑ Parallel Mod/sev N=60 | H.04.03 | Side effects | Mid (12) | Erythromycin acistrate Any event 11 None 18 | Tetracycline Any effect 9 None 20
| | Side effects | Long (24) | Any effect 3 None 18 | Any effect 3 None 18
4 ↑ Parallel N=30 | H.04.05 | Severity change (akamatsu) | Mid (8) | Roxithromycin (150) Worsening 2 No change 1 Slight improvement 1 Moderate improvement 10 | Roxithromycin (300) Worsening 0 No change 2 Slight improvement 2 Moderate improvement 7
| | | | Good improvement 1 | Good improvement 4
247 Parallel N=142 | H.04.06 | Overall change/physician | Short (6) | Oleandomycin Excellent 11 Good 23 Negative 19 | Triacetyl-oleandomycin Excellent 28 Good 44 Negative 17
161 ↑ Cross-over N=43 | H.05.01 | Side effects | Short (5) | Minocycline Vertigo (withdraw) 1 Urticaria (withdraw) 1 | Placebo Vertigo (withdraw) 0 Urticaria (withdraw) 0
268 ↑ Parallel Mod/sev N=80 | H.05.02 | Overall change/patient | Mid (12) | Minocycline Much improved/ improved 37 Not changed/ worse/ much worse 1 | Clindamycin Much improved/improved 40 Not changed/ worse/ much worse 2
| | Side effects | Mid (12) | Facial allergy (withdraw) 0 Urticaria (withdraw) 1 Impetiginisation 0 Dryness 0 | Facial allergy (withdraw) 1 Urticaria (withdraw) 0 Impetiginisation 1 Dryness 1
307 ↑ Parallel Mod/sev N=64 | H.05.02 | Facial stinging | Mid (12) | Diarrhea/ ahd 1 Minocycline + placebo Present 1 | Diarrhea/ ahd 0 Clindamycin phosphate + placebo Present 1
72 ↑ Parallel Mod/sev N=100 | H.05.04 | Side effects | Long (19) | Minocycline Vaginal candidiasis (withdraw) 1 Persistent headache (withdraw) 1 Dizzy/loss of vision (withdraw) 0 | Tetracycline Vaginal canididiasis (withdraw) 1 Persistent headache (withdraw) 0 Dizzy/loss of vision (withdraw) 1
298 Parallel Mod/sev N=62 | | GI symtoms | Mid (12) | Mild nausea 1 Moderate nausea 1 Moderate pain 0 None 28 | Mild nausea 2 Moderate nausea 0 Moderate pain 1 None 29
| | Vaginal infection | Mid (12) | Mild 0 Moderate 0 None 30 | Mild 2 Moderate 2 None 28 | NS
250 Cross-over Mod/sev N=76 | H.06.01 | Side effects | | Oxytetracycline Present 0 | Placebo Present 0
250 Cross-over Mod/sev N=76 | | Severity change [phase i] | Mid (10) | Excellent 31 Good 20 Fair 3 Poor 1 | Excellent 1 Good 5 Fair 10 Poor 5
| | Severity change [phase ii] | Mid (10) | Unchanged 0 Excellent 13 Good 7 Fair 1 Poor 0 | Unchanged 0 Excellent 2 Good 8 Fair 25 Poor 13
| | | | Unchanged 0 | Unchanged 4
255 Parallel Mod N=69 | H.06.02 | Side effects | Mid (12) | Oxytetracycline (oral) + vehicle Severe facial reaction 0 GI symptoms 2 GI symptoms 2 Vaginal candidiasis 0 | Benzoyl peroxide + placebo (oral) Severe facial reaction 1 GI symptoms 2 Vaginal candidiasis 1
123 Parallel Mod/sev N=52 | H.06.03 | Overall change/patient | Short (6) | Oxytetracycline + vehicle Much worse 0 Worse 1 Unchanged 3 Somewhat improved 4 | Benzoyl peroxide + metronidazole + placebo Much worse 0 Worse 0 Unchanged 1 Somewhat improved 2 | NS
| | Overall change/physician | Short (6) | Improved 6 Much improved 9 0-25% 2 26-50% 4 51-75% 6 76-100% 11 | Improved 8 Much improved 12 0-25% 1 26-50% 2 51-75% 8 76-100% 12 | NS
| | Severity change/photo | Short (6) | 0-25% 3 26-50% 4 51-75% 4 76-100% 12 | 0-25% 1 26-50% 3 51-75% 10 76-100% 9 | NS
255 Parallel N=69 | H.06.05 | Side effects | Mid (12) | Oxytetracycline (oral) + vehicle Severe facial reaction 0 Mod GI symptoms 2 Vaginal candidiasis 0 | Tetracycline (topical) + placebo (oral) Severe facial reaction 0 GI symptoms 2 Vaginal candidiasis 0
152 ↑ Parallel Mild/mod/sev N=16 | H.06.06 | Overall change/matched (vas) | Short (4) | Oxytetracycline Co-tri better 3 Oxytet better 2 Both the same 2 | Trimethoprim + sulfamethoxazole Co-tri better 3 Oxytet better 2 Both the same 2 | NS
| | Inter-treatment severity comparison | Mid (12) | Papules 2 Pustules 2 | Papules 6 Pustules 6
| | Overall change/matched (vas) | Mid (12) | Co-trimax better 2 Oxytet better 2 Both the same 4 | Co-trimax better 2 Oxytet better 2 Both the same 4 | NS
| | Severity change/photo | Mid (12) | Considerable 4 Partial 2 None 2 | Considerable 5 Partial 3 None 0
| | Side effects | Mid (12) | Flatulence/ abdominal pain 1 None 7 | Flatulence/ abdominal pain 0 None 8
128 ↑ Parallel Mild N=45 | H.06.07 | Overall change/patient | Short (4) | Oxytetracycline Excellent 1 Good 1 Fair 18 No change 3 | Trimethoprim Excellent 0 Good 7 Fair 11 No change 3 | NS
| | Side effects | Short (4) | Worse 1 Bad enough to withdraw 0 Headache/abd pain 3 None | Worse 0 Bad enough to withdraw 2 Headache/abd pain 0 None
| | Overall change/patient | Mid (8) | Excellent 0 Good 8 Fair 15 No change 1 | Excellent 2 Good 10 Fair 5 No change 3 | NS
| | | | Worse 0 | Worse 1
223 ↑ Cross-over N=40 | H.07.01 | Dizziness and headaches | Short (4) | Trimethporim-sulfamethoxazole Dizziness and headaches 1 | Placebo Dizziness and headache 0
223 ↑ Cross-over N=40 | | Red macular rash | Short (4) | Macular rash (withdraw) 1 No rash 39 | Macular rash (withdraw) 0 No rash 33
41 ↑ Cross-over Sev N=134 | H.07.02 | Inter-treatment preference/physician | Mid (10) | Sulfadimethoxine More effective 75 Equally effective 37 Less effective 22 | Placebo More effective 22 Equally effective 37 Less effective 75
201 ↑ Parallel N=51 | H.08.01 | Clinical change (grouped) | Mid (12) | Tetracycline Improved 23 No change 0 Worse 1 | Placebo Improved 15 No change 4 Worse 8 | 0.01
| | Clinical change/photo (grouped) | Mid (12) | Improved 18 No change 5 Worse 1 | Improved 9 No change 14 Worse 4 | 0.01
| | Clinical improvement/photo (grouped) | Mid (12) | Improvement 13 No change 11 Worse 0 | Improved 2 No change 20 Worse 5 | 0.01
| | Side effects | Mid (12) | Nausea 0 Pruritis ani 0 Contact lens discomfort 1 | Nausea 0 Pruritis ani 0 Contact lens discomfort 0
69 ↓ Parallel N=68 | H.08.01 | Improvement | Long (16) | Tetracycline Much improvement 36 Little improvement 18 | Topical treatment Much improvement 2 Little improvement 12
| | Side effects | Long (16) | Diarrhea & GI problems 2 | Diarrhea & GI problems 0
10 Parallel Mod N=60 | H.08.01 | Severity change | Mid (8) | Tetracycline (oral) + vehicle (topical) > 1 unit decrease 12 < 1 unit decrease 1 No change 5 | Vehicle (topical) + placebo (oral) > 1 unit decrease 6 < 1 unit decrease 4 No change 7 | NS
33 Parallel Mild N=87 | H.08.01 | Diarrhea | Mid (8) | Tetracycline + vehicle Present 1 | Vehicle (oral) + vehicle (topical) Present 1
| | Overall change/patient | Mid (8) | Marked improvement 11 Improved 10 No change 7 Worse 1 | Marked improvement 0 Improved 1 No change 20 Worse 8
| | Overall change/physcian | Mid (8) | Excellent 11 Good 6 Fair 8 Poor 4 | Excellent 0 Good 0 Fair 4 Poor 25
71 Cross-over N=150 | H.08.01 | Severity change | Short (4) | Tetracycline hydrochloride Worse 10 No change after good response 3 No change 6 Slight 15 | Vehicle Worse 10 No change after good response 2 No change 9 Slight 11 | NS
| | Side effects | Short (4) | Good 4 Excellent 3 Photoreactivity 3 | Good 7 Excellent 3 Photoreactivity 1
33 Parallel Mild N=87 | H.08.02 | Diarrhea | Mid (8) | Tetracycline + vehicle Present 1 | Clindamycin + vehicle Present 1
| | Overall change/patient | Mid (8) | Marked improvement 11 Improved 10 No change 7 Worse 1 | Marked improvement 19 Improved 3 No change 7 Worse 0
| | Overall change/physcian | Mid (8) | Excellent 11 Good 6 Fair 8 Poor 4 | Excellent 17 Good 6 Fair 1 Poor 5
186 ↓ Parallel Mod N=44 | H.08.02 | Side effects | | Tetracycline hydrochloride + placebo Erythema 1 Gastrointestinal upset 1 Diarrhea 1 | Clindamycin + placebo Erythema 0 Gastro-intestinal upset 0 Diarrhea 1
279 ↑ Parallel Mod/sev N=54 | H.08.03 | Overall change/physician, patient | Short (4) | Tetracycline hydrochloride + placebo (topical) Excellent 5 Good 13 Fair 6 Poor 1 | Erythromycin + placebo (oral) Excellent 2 Good 13 Fair 8 Poor 2
| | Closed comedones severity change (vas) | Mid (12) | Worse 0 >50% reduction 6 | Worse 0 >50% reduction 12
| | Open comedones severity change (vas) | Mid (12) | >50% reduction 14 | >50% reduction 19 | NS
| | Overall change/physician, patient | Mid (12) | Excellent 4 Good 10 Fair 5 Poor 3 | Excellent 17 Good 12 Fair 6 Poor 0 | NS
| | Papules severity change (vas) | Mid (12) | Worse 0 >50% reduction 15 | Worse 0 >50% reduction 19 | NS
| | Pustules severity change (vas) | Mid (12) | >50% reduction 14 | >50% reduction 20 | NS
| | Withdrawals due to side effects | Mid (12) | Withdraw 2 | Withdraw 0
10 Parallel Mod N=60 | H.08.04 | Severity change | Mid (8) | Tetracycline (oral) + vehicle (topical) > 1 unit decrease 12 < 1 unit decrease 1 No change 5 | Tetracycline (topical) + placebo (oral) > 1 unit decrease 14 < 1 unit decrease 3 No change 2 | NS
22 ↓ Parallel Mod/sev N=45 | H.08.05 | Abdominal pain | Long (24) | Tetracycline + placebo Present 1 Absent 21 | Azelaic acid + placebo Present 0 Absent 23
166 ↑ Parallel Mild/mod N=333 | H.08.05 | Overall change/physician | Mid (12) | Tetracycline hydrochloride Excellent/good 127 Other 42 | Azelaic acid + placebo Excellent/good 115 Other 49
| | Overall change/physician | Long (20) | Excellent/good 145 Other 24 | Excellent/good 134 Other 30 | NS
167 ↑ Parallel Mod/sev N=261 | H.08.05 | Overall change/patient | Long (24) | Tetracycline hydrochloride + placebo Good or excellent 82 Other 53 | Azelaic acid + placebo Good or excellent 78 Other 48
317 ↑ Parallel Sev N=51 | H.08.08 | Severity change | Mid (12) | Tetracycline Much improved 13 Not improved 12 | Tetracycline + proteolytic enzymes Much improved 18 Not improved 8 | NS
212 ↑ Parallel N=55 | H.08.08 | Overall change/physician | Short (4) | Tetracycline (sustained release) Improved 11 No change 10 Worse 0 | Tetracycline hydrochloride Improved 11 No change 5 Worse 2 | NS
| | Overall change/physician | Mid (12) | Improved 15 No change 6 Worse 0 | Improved 13 No change 5 Worse 0 | NS
| | Side effects | Mid (12) | Diarrhea 1 Sore mouth 1 | Diarrhea 0 Sore mouth 0
299 ↑ Parallel Mod/sev N=42 | H.08.085 | Overall change/physician | Short (4) | Tetracycline + sodium novobiocin Improved 18 Not improved 5 | Placebo Improved 9 Not improved 10 | 0.04
299 ↑ Parallel Mod/sev N=42 | | Side effects | Short (4) | Diarrhea 0 Dryness of oral mucous 0 Headache 1 Low seeing theshold 1 | Diarrhea 1 Dryness of oral mucous 1 Headache 0 Low seeing theshold 0
| | | | Macular drug reaction 1 | Macular drug reaction 0
236 ↓ Parallel Mod/sev N=30 | H.08.14 | Itching | Long (14) | Povidone-iodine + tetracycline Itching 0 | Tetracycline + vehicle Itching 0
| | Overall change/physician | Long (14) | Improved or much improved 10 No change or worse 3 | Improved or much improved 12 No change or worse 2
293 ↑ Parallel Mild/mod/sev N=46 | H.09.01 | Severity change | | Dapsone Greatly improved 9 Improved 3 Not improved 9 | Placebo Greatly improved 3 Improved 2 Not improved 18 | 0.05
| | Severity change [female] | | Greatly improved 5 Improved 2 Not improved 2 | Greatly improved 1 Improved 1 Not improved 14 | 0.01
| | Severity change [male] | | Greatly improved 4 Improved 1 Not improved 7 | Greatly improved 2 Improved 1 Not improved 4
| | Side effects | | Present 6 | Present 3
| | Side effects [Female] | | Present 4 | Present 0 | 0.1
| | Side effects [Male] | | Present 2 | Present 3
312 ↑ Parallel Mild/mod/sev N=66 | H.09.02 | Overall change/physician | Short (4) | Phenethicillin Improved 5 No change 10 Worse 1 Not assessed 4 | Placebo Improved 3 No change 13 Worse 0 Not assessed 6 | NS
344 ↑ Parallel Mild/mod/sev N=70 | H.09.04 | Overall change/physician | Short (2) | Sodium fusidate (oral) No effect 14 Improved 22 Completely resolved 1 | Sodium fusidate (topical) No effect 13 Improved 18 Completely resolved 0
| | Severity change/photo | Short (2) | Improved 11 Worse 6 No difference 19 | Improved 11 Worse 2 No difference 15
| | Side effects | Short (2) | Gastric irritation 7 | Gastric irritation 0

TRIAL: ↑↓ -presence of positive or negative methodological features (see Summary Table). “Mild/mod,” etc., -our assessment of entry severity of study patients. “P”- to parallel study, “S”-split face design. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table i1. Articles/arms for class ANTI-BACTERIAL (ORAL)./KERATOLYTIC (TOPICAL)

Comp-Trial | | TARGET | | HEADING | | COMPARATOR | | Outcome Table(s)
Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment
I.01.01 | 126 | Cotrimoxazole Sulphur/resorcinol/salicylic acid | 2 tablets oral bid. No dose information. | | Cotrimoxazole Placebo | 2 tablets oral bid. No dose information. | | Discrete
I.01.02 | 126 | Cotrimoxazole Sulphur/resorcinol/salicylic acid | 2 tablets oral bid. No dose information. | | Cotrimoxazole Tretinoin | 2 tablets topical qd. 0.05 % topical qd. | Cotrimoxazole every other week. | Discrete
I.02.01 | 323 | Polyethylene scrub Sulphur/salicylic acid Tetracycline | No dose information. No dose information. 250 mg oral bid. | | Water avoidance Benzoyl peroxide Tretinoin | No dose information. 5 % topical tid. 0.05 % topical qhs. | | Continuous

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table I2: DISCRETE outcomes for class ANTI-BACTERIAL (ORAL)./KERATOLYTIC (TOPICAL)

Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Treatment | Comparator | Between P-value
Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Attribute: Number of patient | Attribute: Number of patients | Between P-value
| I.01.01 | | | Sulfur-resorcinol + cotrimoxazole | Placebo + cotrimoxazole
126 ↑ Parallel N=211 | | Severity change (severity) | Short (5) | Very good (>75% reduction) 7 Good (50-75% reduction) 15 Moderate (25-49% reduction) 24 Poor (<25% reduction) 8 | Very good (>75% reduction) 2 Good (50-75% reduction) 6 Moderate (25-49% reduction) 16 Poor (<25% reduction) 12 | 0.001
| | | | No change/worse 4 | No change/worse 12
| | Comedones change (count) | Mid (7) | Very good + good (>50%) 23 Less than very good improved (50%) 29 | Very good + good (>50%) 6 Less than very good improved (50%) 34 | 0.001
| | Desquamation | Mid (7) | Absent 52 Slight 18 Moderate 1 Withdraw 0 | Absent 57 Slight 14 Moderate 0 Withdraw 0
| | Erythema | Mid (7) | Absent 39 Slight 15 Moderate 6 Withdraw 5 | Absent 47 Slight 2 Moderate 2 Withdraw 0
| | Papules change (count) | Mid (7) | Very good + good improved (>50%) 22 Less than very good (<50%) 30 | Very good + good improved (>50%) 6 Less than very good (<50%) 31 | 0.001
| | Pustules change (count) | Mid (7) | Very good + good (>50%) 26 Less than very good improved (<50%) 26 | Very good + good (>50%) 19 Less than very good improved (<50%) 18 | NS
| | Severity change (severity) | Mid (7) | Very good (>75% reduction) 8 Good (50-75% reduction) 24 Moderate (25-49% reduction) 15 Poor (1-24% reduction) 16 | Very good (>75% reduction) 4 Good (50-75% reduction) 5 Moderate (25-49% reduction) 20 Poor (1-24% reduction) 20 | 0.001
| | | | Unchanged (0% reduction) 4 Worse (<0% reduction) 4 | Unchanged (0% reduction) 17 Worse (<0% reduction) 5
| I.01.02 | | | Sulfur-resorcinol + cotrimoxazole | Tretinoin + cotrimoxazole
126 ↑ Parallel N=211 | | Severity change (severity) | Short (5) | Very good (>75% reduction) 7 Good (50-75% reduction) 15 Moderate (25-49% reduction) 24 Poor (<25% reduction) 8 | Very good (>75% reduction) 20 Good (50-75% reduction) 22 Moderate (25-49% reduction) 12 Poor (<25% reduction) 8 | 0.001
| | | | No change/worse 4 | No change/worse 1
| | Comedones change (count) | Mid (7) | Very good + good (>50%) 23 Less than very good improved (50%) 29 | Very good + good (>50%) 42 Less than very good improved (50%) 17 | 0.001
| | Desquamation | Mid (7) | Absent 52 Slight 18 Moderate 1 Withdraw 0 | Absent 33 Slight 21 Moderate 14 Withdraw 0
| | Erythema | Mid (7) | Absent 39 Slight 15 Moderate 6 Withdraw 5 | Absent 17 Slight 34 Moderate 24 Withdraw 19
| | Papules change (count) | Mid (7) | Very good + good improved (>50%) 22 Less than very good (<50%) 30 | Very good + good improved (>50%) 41 Less than very good (<50%) 18 | 0.001
| | Pustules change (count) | Mid (7) | Very good + good (>50%) 26 Less than very good improved (<50%) 26 | Very good + good (>50%) 44 Less than very good improved (<50%) 15 | NS
| | Severity change (severity) | Mid (7) | Very good (>75% reduction) 8 Good (50-75% reduction) 24 Moderate (25-49% reduction) 15 Poor (1-24% reduction) 16 | Very good (>75% reduction) 32 Good (50-75% reduction) 17 Moderate (25-49% reduction) 7 Poor (1-24% reduction) 10 | 0.001
| | | | Unchanged (0% reduction) 4 Worse (<0% reduction) 4 | Unchanged (0% reduction) 1 Worse (<0% reduction) 2

TRIAL:↑↓-presence of positive or negative methodological features (see Summary Table). “Mild/mod,” etc., -our assessment of entry severity of study patients. “P”- to parallel study, “S”-split face design. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table J1. Articles/arms for class ANTI-BACTERIAL (ORAL)/RETINOID (TOPICAL)

Comp-Trial | | TARGET | | HEADING | | COMPARATOR | | Outcome Table(s)
Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment
J.01.01 | 126 | Cotrimoxazole Tretinoin | 2 tablets topical qd. 0.05 % topical qd. | Cotrimoxazole every other week. | Cotrimoxazole Placebo | 2 tablets oral bid. No dose information. | | Discrete
J.01.02 | 57 | Oxytetracycline Vitamin A | 250 mg oral qd. 0.05 % topical qd. | Bid for week 1; qd for 7 weeks remaining. | Oxytetracycline Vehicle | 250 mg oral qd. No dose information. | | Discrete
J.01.03 | 323 | Tetracycline Emollient Tretinoin | 250 mg oral bid. No dose information. 0.05 % topical qhs. | | Polyethylene scrub Sulphur/salicylic acid Tetracycline | No dose information. No dose information. 250 mg oral bid. | | Continuous

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table J2. CONTINUOUS outcomes for class ANTI-BACTERIAL (ORAL)/RETINOID (TOPICAL)

Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Target | | Comparator | | Between P-value
Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Data Type: Mean (SD) | Within P | Data Type: Mean (SD) | Within P | Between P-value
| | J.01.03 | | | Tretinoin + emollient + tetracycline | | Tetracycline + sulfur/salicylic acid + polyethyle
323 ↑ Parallel | N=122 Mild/mod/sev | | Comedones change (%) Between P-value: Tret/Tet vs Tret/BP .05 ; Tret/BP vs Tet/Sul NS. | Short (4) | Percent change: −25 | | Percent change: −3
| | | Papules+pustules change (%) Between P-value: Tret/Tet vs Tret/BP NS ; Tret/BP vs Tet/Sul NS. | Short (4) | Percent change: −42 | | Percent change: −40
| | | Total lesions change (%) Between P-value: Tret/Tet vs Tret/BP .05 ; Tret/BP vs Tet/Sul NS. | Short (4) | Percent change: −30 (30.) | | Percent change: −15 (40.)
| | | Comedones change (%) | Mid (12) | Percent change: −63 | | Percent change: −40
| | | Comedones change (%) Between P-value: Tret/Tet vs Tret/BP .001 ; Tret/BP vs Tet/Sul NS. | Mid (12) | Percent change: −65 | | Percent change: −40
| | | Inflammatory change (%) Between P-value: Tret/Tet vs Tret/BP .05 ; Tret/BP vs Tet/Sul .05. | Mid (12) | Percent change: −75 | | Percent change: −50
| | | Total lesions change (%) Between P-value: Tret/Tet vs Tret/BP .01 ; Tret/BP vs Tet/Sul NS. | Mid (12) | Percent change: −68 (30.) | | Percent change: −45 (40.)
| | | Dryness Between P-value: Tret/Tet vs Tret/BP .001 ; Tret/BP vs Tet/Sul NS. | Long (16) | Measure: 0 | | Measure: 1
| | | Erythema Between P-value: Tret/Tet vs Tret/BP NS ; Tret/BP vs Tet/Sul NS. | Long (16) | Measure: 0 | | Measure: 0
| | | Inflammatory change (%) Between P-value: Tret/Tet vs Tret/BP .05 ; Tret/BP vs Tet/Sul NS. | Long (16) | Percent change: −75 | | Percent change: −53
323 ↑ Parallel | N=122 Mild/mod/sev | | Oiliness Between P-value: Tret/Tet vs Tret/BP NS ; Tret/BP vs Tet/Sul NS. | Long (16) | Measure: 0 | | Measure: 0
| | | Peeling | Long (16) | Measure: 0 | | Measure: 1
| | | Total lesions change (%) Between P-value: Tret/Tet vs Tret/BP .001 ; Tret/BP vs Tet/Sul NS. | Long (16) | Percent change: −70 (40.) | | Percent change: −45 (40.)

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., -our assessment of entry severity of study patients. “P”- to parallel study, “S”-split face design. TARGET and COMPARATOR: “Percent change”- an outcome derived from individual final and baseline measures; “Percent change*”- we calculated a group-based percentage change; “Change” - raw difference from baseline; “Change*” - calculated change; “Measure” - an outcome measure with no baseline comparison. SD: standard deviation. WITHIN P: P-value with respect to baseline in one arm. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table J3: DISCRETE outcomes for class ANTI-BACTERIAL (ORAL)/RETINOID (TOPICAL)

Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Treatment | Comparator | Between P-value
Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Attribute: Number of patient | Attribute: Number of patients | Between P-value
| J.01.02 | | | Vitamin A + oxytetracycline | Vehicle + oxytetracycline
57 ↑ Parallel N=238 | | Side effects | | Erythema alone 11 Desquamation alone 3 Erythema + desquamation 52 Itching or pain 4 | Erythema alone 10 Desquamation alone 6 Erythema + desquamation 7 Itching or pain 2 | NS
| | | | Vomiting or nausea 0 Diarrhea 0 fatigue 0 | Vomiting or nausea 2 Diarrhea 0 Fatigue 0
| | Side effects | | Any side effects 66 No side effects 13 | Any side effects 25 No side effects 54 | NS
| | Comedones change | Mid (8) | Worse 2 No change 2 0-49% reduction 11 50-74% reduction 20 | Worse 6 No change 16 0-49% reduction 19 50-74% reduction 25 | NS
| | | | 75-100%, reduction 65 | 75-100%, reduction 34
| | Papules change | Mid (8) | Worse 5 No change 9 0-49% reduction 13 50-74% reduction 25 | Worse 8 No change 8 0--49% reduction 21 50-74% reduction 32 | NS
| | | | 75-100%, reduction 48 | 75-100%, reduction 31
| | Pustules change | Mid (8) | Worse 2 No change 11 0-49% reduction 50-74% reduction 13 | Worse 2 No change 5 0-49% reduction 9 50-74% reduction 24 | NS
| | | | 75-100%, reduction 74 | 75-100%, reduction 60

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “Mild/mod,” etc., -our assessment of entry severity of study patients. “P”- to parallel study, “S”-split face design. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table K1. Articles/arms for class RETINOID (ORAL)

Comp-Trial | | TARGET | | HEADING | | COMPARATOR | | Outcome Table(s)
Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment
K.02.01 | 269 | Isotretinoin | 0.5 mg/kg oral (can't say) | | Placebo | No dose information. | | Continuous Discrete
K.02.02 | 276 | Isotretinoin | 40 mg oral qd. | | Dapsone | 100 mg oral qd. | | Continuous Discrete
K.02.03 | 206 | Isotretinoin | 1 mg\kg\day oral qd. | Dosage increments of 0.5 mg/kg/day were permitted at biweekly intervals to a maximum dose of 2.0 mg/kg/day. Number of doses per day not specified. | Tetracycline hydrochloride | 1000 mg oral qd. | Starting at 250mg/d dosage increments of 250mg/day. | Continuous Discrete
K.02.04 | 127 | Isotretinoin | 20 mg oral qd. | With main meal. | Alitretinoin | 20 mg oral qd. | With main meal. | Discrete
K.02.05 | 130 | Isotretinoin | 0.5 mg/kg oral bid. | Provided to nearest 10 mg/kg capsule. Hydrocortisone ointiment 1% as needed.. | Etretinate | 0.5 mg/kg oral qd. | Provided to nearest 10 mg capsule. Hydrocortisone ointment 1 % is needed.. | Continuous Discrete
K.02.06 | 5 | Isotretinoin | 0.5 mg/kg oral qd. | | Isotretinoin | 0.3 mg/kg oral qd. | | Discrete
| | Isotretinoin | 0.5 mg/kg oral qd. | | Isotretinoin | 0.1 mg/kg oral qd. | | Discrete
| | Isotretinoin | 0.3 mg/kg oral qd. | | Isotretinoin | 0.1 mg/kg oral qd. | | Discrete
| 106 | Istretinoin | 0.05 mg/kg oral bid. | Hydrocortisone 1% + emollient. | Isotretinoin | 0.5 mg/kg oral bid. | Hydrocortisone 1% + emollient.
| 185 | Isotretinoin | 1 mg/kg oral (can't say) | | Isotretinoin | 0.1 mg/kg oral (can't say) | | Continuous Discrete
| | Isotretinoin | 1 mg/kg oral (can't say) | | Isotretinoin | 0.5 mg/kg oral (can't say) | | Continuous Discrete
| | Isotretinoin | 0.5 mg/kg oral (can't say) | | Isotretinoin | 0.1 mg/kg oral (can't say) | | Continuous Discrete
| 190 | | | | Isotretinoin | 1 mg/kg oral (can't say)
| 320 | Isotretinoin | 0.5 mg/kg oral qd. | | Isotretinoin | 1 mg/kg oral qd. | | Continuous Discrete
| | Isotretinoin | 0.5 mg/kg oral qd. | | Isotretinoin | 0.1 mg/kg oral qd. | | Continuous Discrete
K.02.06 | 320 | Isotretinoin | 1 mg/kg oral qd. | | Isotretinoin | 0.5 mg/kg oral qd. | | Continuous Discrete
| | Isotretinoin | 1 mg/kg oral qd. | | Isotretinoin | 0.1 mg/kg oral qd. | | Continuous Discrete
| 332 | Isotretinoin | 1 mg/kg oral (can't say) | | Isotretinoin | 0.5 mg/kg oral qd. | No concomitant topical or systemic acne therapy.. | Continuous Discrete
K.03.01 | 12 | Vitamin A | 50000 iu oral tid. | Ancillary treatment was allowed but not required. Sulfurated potash and zinc lotion, topically. | Placebo | No dose information. | | Discrete
K.03.02 | 233 | Vitamin A palmitate | 15000 IU oral bid. | Dispatabs^®^ (US); 150,000 IU bid if 60kg or less, or 200,000 IU if over 60kg. | Zinc sulfate | 0.2 g oral tid. | Dissolved in water and taken after meals. | Continuous (M) Discrete

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table K2. CONTINUOUS outcomes for class RETINOID (ORAL)

Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Target | | Comparator | | Between P-value
Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Data Type: Mean (SD) | Within P | Data Type: Mean (SD) | Within P | Between P-value
| | K.02.01 | | | Isotretinoin | | Placebo
269 ↑ Parallel | N=33 Sev | | Cysts change (%) | Short (4) | Percent change: −17 | | Percent change: 33 | | 0.001
| | K.02.02 | | | Isotretinoin | | Dapsone
276 Parallel | N=40 Sev | | Chest/back total lesions (count) Baseline counts: 38 (Target)/39 (Comparator) | Short (4) | Percent Change*: −53 | | Percent Change*: −33 | NS | NS*
| | | Face/neck total lesions (count) Baseline counts: 25 (Target)/21 (Comparator) | Short (4) | Percent Change*: −64 | | Percent Change*: −38 | | NS*
| | | Overall change/patient vas (p-value) | Short (4) | Measure: 0 | .01 | Measure: 1 | NS
| | | Total severity/photo (leeds) | Short (4) | Measure: 5 (3.6) | NS | Measure: 5 (2.4) | NS | NS*
| | | Chest/back total lesions (count) Baseline counts: 38 (Target)/39 (Comparator) | Mid (8) | Percent Change*: −66 | NS | Percent Change*: −36 | NS | NS*
| | | Face/neck total lesions (count) Baseline counts: 25 (Target)/21 (Comparator) | Mid (8) | Percent Change*: −76 | | Percent Change*: −43 | | NS*
| | | Overall change/patient vas (p value) | Mid (8) | Measure: 0 | .001 | Measure: 0 | .05
| | | Total severity/photo (leeds) | Mid (8) | Measure: 5 (3.6) | .01 | Measure: 6 (4.) | NS | NS*
| | | Chest/back total lesions (count) Baseline counts: 38 (Target)/39 (Comparator) | Long (16) | Percent Change*: −89 | .01 | Percent Change*: −36 | NS | NS*
| | | Face/neck total lesions (count) Baseline counts: 25 (Target)/21 (Comparator) | Long (16) | Percent Change*: −88 | .0001 | Percent Change*: −57 | .05
| | | Overall change/patient vas (p value) | Long (16) | Measure: 0 | .001 | Measure: 0 | .01
| | | Total severity/photo (leeds) | Long (16) | Measure: 5 (4.) | .01 | Measure: 6 (3.6) | NS | NS*
276 Parallel | N=40 Sev | | Post-therapy chest/back total lesions (count) Baseline counts: 38 (Target)/39 (Comparator) | Long (36) | Percent Change*: −89 | .01 | Percent Change*: −33 | NS | NS*
| | | Post-therapy face/neck total lesions (count) Baseline counts: 25 (Target)/21 (Comparator) | Long (36) | Percent Change*: −92 | .0001 | Percent Change*: −57 | | 0.01
| | | Post-therapy overall change/patient vas (p value | Long (36) | Measure: 0 | .001 | Measure: 1 | NS
| | | Post-therapy total severity/photo (leeds) | Long (36) | Measure: 3 (3.6) | .0005 | Measure: 7 (3.) | .01 | NS*
| | K.02.03 | | | Isotretinoin | | Tetracycline hydrochloride
206 ↓ Parallel | N=30 Sev | | Comedones+pustules (count) Baseline counts: 27 (Target)/18 (Comparator) | Short (4) | Percent Change*: −40 | | Percent Change*: −49 | | NS*
| | | Cysts (count) Baseline counts: 21 (Target)/23 (Comparator) | Short (4) | Percent Change*: −25 | | Percent Change*: −29 | | NS*
| | | Cysts diameters (mm) | Short (4) | Measure: 140 (100.) | | Measure: 135 (80.) | | NS*
| | | Comedones+pustules (count) Baseline counts: 27 (Target)/18 (Comparator) | Mid (12) | Percent Change*: −66 | | Percent Change*: −38 | | NS*
| | | Cysts (count) Baseline counts: 21 (Target)/23 (Comparator) | Mid (12) | Percent Change*: −53 | | Percent Change*: −47 | | NS*
| | | Cysts diameters (mm) | Mid (12) | Measure: 90 (70.) | | Measure: 100 (100.) | | NS*
| | | Post-therapy long term cyst (count) Baseline counts: 21 (Target)/23 (Comparator) | Long (34) | Percent Change*: −85 | | Percent Change*: −73 | | 0.02
| | | Post-therapy comedones+pustules (count) Baseline counts: 27 (Target)/18 (Comparator) | Long (35) | Percent Change*: −94 | | Percent Change*: −60 | | 0.01
| | | Post-therapy cyst diameters (mm) | Long (35) | Measure: 31 (57.6) | | Measure: 57 (66.5) | | 0.01
| | K.02.05 | | | Isotretinoin | | Etretinate
130 Parallel | N=56 Sev | | Nodulocystic change (%) Count location: Face unspecified. | Short (4) | Percent change: −20 | | Percent change: −5
| | | Nodulocystic change/face (%) | Short (4) | Percent change: −39 | | Percent change: −19
| | | Nodulocystic change (%) | Mid (8) | Percent change: −43 | | Percent change: −8 | | 0.05
| | | Nodulocystic change/face (%) | Mid (8) | Percent change: −68 | | Percent change: −20 | | 0.05
| | | Nodulocystic change post-therapy (%) | Long (16) | Percent change: −69 | | Percent change: −33 | | 0.05
| | | Nodulocystic change post-treatment/face (%) | Long (16) | Percent change: −72 | | Percent change: −29 | | 0.05
| | K.02.06 | | | Isotretinoin (0.1) | | Isotretinoin (1.0)
190 Parallel | N=48 Mild/mod/sev | | Severity/face (king) Count location: Face unspecified. | Short (4) | Measure: 2 | | Measure: 2 (1.5) | | NS
106 Parallel | N=16 Sev | | Cystic change (%) Count location: Designated area of face, chest and/or back. | Short (6) | Percent change: −16 | | Percent change: −44 | | NS
| | | Cystic diameter change (%) | Short (6) | Percent change: −20 | | Percent change: −63 | | NS
| | | Cheilitis duration (%) | Mid (12) | Percent change: 11 | | Percent change: 12
| | | Cystic change (%) Count location: Designated area of face, chest and/or back. | Mid (12) | Percent change: −49 | | Percent change: −65 | | NS
| | | Cystic diameter change (%) | Mid (12) | Percent change: −57 | | Percent change: −76 | | NS
| | | Desquamation duration (week) | Mid (12) | Measure: 7 | | Measure: 12
| | | Puritus duration (weeks) | Mid (12) | Measure: 5 | | Measure: 8
190 Parallel | N=48 Mild/mod/sev | | Severity/face (king) Count location: Face unspecified. | Mid (12) | Measure: 1 (0.4) | | Measure: 1 | | NS
| | | Severity/face (king) | Long (16) | Measure: 0 (0.7) | | Measure: 1 | | NS
106 Parallel | N=16 Sev | | Cystic change post-treatment (%) Count location: Designated area of face, chest and/or back. | Long (20) | Percent change: −56 | | Percent change: −88 | | NS
| | | Cystic diameter change post-treatment | Long (20) | Measure: −67 | | Measure: −91 | | NS
| | K.02.06 | | | Isotretinoin (0.5) | | Isotretinoin (0.1)
320 Parallel | N=150 Sev | | Inflammatory change/face (%) Count location: Face unspecified. | Short (4) | Percent change: −15 | | Percent change: −28 | | NS
| | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. | Short (4) | Percent change: −20 | | Percent change: −30 | | 0.01
185 ↑ Parallel | N=76 Mod | | Non-inflammatory change (%) | Short (4) | Percent change: −39 | | Percent change: −22 (72.4)
320 Parallel | N=150 Sev | | Inflammatory change/face (%) Count location: Face unspecified. | Mid (12) | Percent change: −67 | | Percent change: −72 | | 0.01
| | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. Between P-value: .05 > 1.0. | Mid (12) | Percent change: −48 | | Percent change: −52 | | 0.05
185 ↑ Parallel | N=76 Mod | | Non-inflammatory change (%) | Mid (12) | Percent change: −73 (47.7) | | Percent change: −66
| | | Non-inflammatory change (%) | Long (16) | Percent change: −83 (34.1) | | Percent change: −80
320 Parallel | N=150 Sev | | Inflammatory change/face (%) Count location: Face unspecified. | Long (20) | Percent change: −77 | | Percent change: −77 | | 0.01
| | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. | Long (20) | Percent change: −68 | | Percent change: −58 | | 0.01
| | | Inflammatory change post therapy/face (%) Count location: Face unspecified. | Long (32) | Percent change: −90 | | Percent change: −90 | | 0.01
| | | Inflammatory change/trunk post-therapy (%) Count location: Back or chest unspecified. | Long (32) | Percent change: −80 | | Percent change: −88 | | 0.01
185 ↑ Parallel | N=76 Mod | | Post-therapy non-inflammatory change (%) | Long (32) | Percent change: −91 | | Percent change: −89 (20.1)
| | K.02.06 | | | Isotretinoin (0.5) | | Isotretinoin (1.0)
320 Parallel | N=150 Sev | | Inflammatory change/face (%) Count location: Face unspecified. | Short (4) | Percent change: −15 | | Percent change: −32 | | NS
| | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. | Short (4) | Percent change: −20 | | Percent change: −5 | | 0.01
| | | Inflammatory change/face (%) Count location: Face unspecified. | Mid (12) | Percent change: −67 | | Percent change: −70 | | 0.01
320 Parallel | N=150 Sev | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. Between P-value: .05 > 1.0. | Mid (12) | Percent change: −48 | | Percent change: −24 | | 0.05
| | | Inflammatory change/face (%) Count location: Face unspecified. | Long (20) | Percent change: −77 | | Percent change: −90 | | 0.01
| | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. | Long (20) | Percent change: −68 | | Percent change: −56 | | 0.01
| | | Inflammatory change post therapy/face (%) Count location: Face unspecified. | Long (32) | Percent change: −90 | | Percent change: −95 | | 0.01
| | | Inflammatory change/trunk post-therapy (%) Count location: Back or chest unspecified. | Long (32) | Percent change: −80 | | Percent change: −78 | | 0.01
| | K.02.06 | | | Isotretinoin (1.0) | | Isotretinoin (0.1)
320 Parallel | N=150 Sev | | Inflammatory change/face (%) Count location: Face unspecified. | Short (4) | Percent change: −32 | | Percent change: −28 | | 0.01
| | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. | Short (4) | Percent change: −5 | | Percent change: −30 | | NS
185 ↑ Parallel | N=76 Mod | | Non-inflammatory change (%) | Short (4) | Percent change: −48 (38.7) | | Percent change: −22 (72.4)
320 Parallel | N=150 Sev | | Inflammatory change/face (%) Count location: Face unspecified. | Mid (12) | Percent change: −70 | | Percent change: −72 | | 0.01
| | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. Between P-value: 1.0 < 0.5. | Mid (12) | Percent change: −24 | | Percent change: −52 | | NS
185 ↑ Parallel | N=76 Mod | | Non-inflammatory change (%) | Mid (12) | Percent change: −81 (35.) | | Percent change: −66
| | | Non-inflammatory change (%) | Long (16) | Percent change: −88 (15.4) | | Percent change: −80
320 Parallel | N=150 Sev | | Inflammatory change/face (%) Count location: Face unspecified. | Long (20) | Percent change: −90 | | Percent change: −77 | | 0.01
| | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. | Long (20) | Percent change: −56 | | Percent change: −58 | | 0.01
| | | Inflammatory change post therapy/face (%) Count location: Face unspecified. | Long (32) | Percent change: −95 | | Percent change: −90 | | 0.01
320 Parallel | N=150 Sev | | Inflammatory change/trunk post-therapy (%) Count location: Back or chest unspecified. | Long (32) | Percent change: −78 | | Percent change: −88 | | 0.01
185 ↑ Parallel | N=76 Mod | | Post-therapy non-inflammatory change (%) | Long (32) | Percent change: −94 (14.7) | | Percent change: −89 (20.1)
| | K.02.06 | | | Isotretinoin (1.0) | | Isotretinoin (0.5)
332 Parallel | N=58 Mild/mod/sev | | Comedones (median) Count location: Unspecified. | Short (4) | Measure: 100 | | Measure: 120
| | | Infiltrates (median) | Short (4) | Measure: 7 | | Measure: 5
320 Parallel | N=150 Sev | | Inflammatory change/face (%) Count location: Face unspecified. | Short (4) | Percent change: −32 | | Percent change: −15 | | 0.01
| | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. | Short (4) | Percent change: −5 | | Percent change: −20 | | NS
185 ↑ Parallel | N=76 Mod | | Non-inflammatory change (%) | Short (4) | Percent change: −48 (38.7) | | Percent change: −39
332 Parallel | N=58 Mild/mod/sev | | Papules (median) Count location: Unspecified. | Short (4) | Measure: 30 | | Measure: 36
| | | Pustules (median) | Short (4) | Measure: 8 | | Measure: 10 | | NS
| | | Comedones (median) | Mid (12) | Measure: 82 | | Measure: 47 | | NS
| | | Infiltrates (median) | Mid (12) | Measure: 7 | | Measure: 5 | | NS
320 Parallel | N=150 Sev | | Inflammatory change/face (%) Count location: Face unspecified. | Mid (12) | Percent change: −70 | | Percent change: −67 | | 0.01
| | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. Between P-value: 1.0 < 0.5. | Mid (12) | Percent change: −24 | | Percent change: −48 | | NS
185 ↑ Parallel | N=76 Mod | | Non-inflammatory change (%) | Mid (12) | Percent change: −81 (35.) | | Percent change: −73 (47.7)
332 Parallel | N=58 Mild/mod/sev | | Papules (median) Count location: Unspecified. | Mid (12) | Measure: 22 | | Measure: 18 | | “Significant”
| | | Pustules (median) | Mid (12) | Measure: 6 | | Measure: 4 | | NS
| | | Side effects (number) | Mid (12) | Measure: 6 | | Measure: 5 | | 0.002
185 ↑ Parallel | N=76 Mod | | Non-inflammatory change (%) | Long (16) | Percent change: −88 (15.4) | | Percent change: −83 (34.1)
320 Parallel | N=150 Sev | | Inflammatory change/face (%) Count location: Face unspecified. | Long (20) | Percent change: −90 | | Percent change: −77 | | 0.01
| | | Inflammatory change/trunk (%) Count location: Back or chest unspecified. | Long (20) | Percent change: −56 | | Percent change: −68 | | 0.01
| | | Inflammatory change post therapy/face (%) Count location: Face unspecified. | Long (32) | Percent change: −95 | | Percent change: −90 | | 0.01
| | | Inflammatory change/trunk post-therapy (%) Count location: Back or chest unspecified. | Long (32) | Percent change: −78 | | Percent change: −80 | | 0.01
185 ↑ Parallel | N=76 Mod | | Post-therapy non-inflammatory change (%) | Long (32) | Percent change: −94 (14.7) | | Percent change: −91

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., -our assessment of entry severity of study patients. “P”- to parallel study, “S”-split face design. TARGET and COMPARATOR: “Percent change”- an outcome derived from individual final and baseline measures; “Percent change*”- we calculated a group-based percentage change; “Change” - raw difference from baseline; “Change*” - calculated change; “Measure” - an outcome measure with no baseline comparison. SD: standard deviation. WITHIN P: P-value with respect to baseline in one arm. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table K3: DISCRETE outcomes for class RETINOID (ORAL)

Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Treatment | Comparator | Between P-value
Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Attribute: Number of patient | Attribute: Number of patients | Between P-value
| K.02.01 | | | Isotretinoin | Placebo
269 ↑ Parallel Sev N=33 | | Reduction in application due to side effects | | Cheilitis 1 Facial dermatitis 1 Artharlgia 1 | Cheilitis 0 Facial dermatitis 0 Artharlgia 0
| K.02.02 | | | Isotretinoin | Dapsone
276 Parallel Sev N=40 | | Side effects | Long (16) | Cheilitis 17 Hypersensitivity reaction (withdraw) 0 | Cheilitis 0 Hypersensitivity reaction (withdraw) 1
| K.02.03 | | | Isotretinoin | Tetracycline hydrochloride
206 ↓ Parallel Sev N=30 | | Integumentary side effects I | | Xerosis 15 Cheilitis/dry lips 15 Desquamation of skin 7 Atopecia 3 | Xerosis 2 Cheilitis/dry lips 3 Desquamation of skin 0 Atopecia 0
| | | | Erythema 3 | Erythema 0
| | Integumentary side effects II | | Pruritis 1 Dry hair 1 Skin flushing 1 Eczema 1 | Pruritis 0 Dry hair 2 Skin flushing 1 Eczema 0
| | | | Tender fingertips 1 | Tender fingertips 0
| | Integumentary side effects III | | Skin fissuring 1 Lesions crusting 1 Morbilliform eruption 0 Herpes simplex 0 | Skin fissuring 0 Lesions crusting 0 Morbilliform eruption 1 Herpes simplex 1
| | | | Epistaxis 10 Dry nose 10 | Epistaxis 0 Dry nose 1
| | Systemic reactions | | Increased thirst 0 Dry mouth 3 Indigestion 0 | Increased thirst 2 Dry mouth 1 Indigestion 1
206 ↓ Parallel Sev N=30 | | Systemic reactions/Special senses | | Conjunctivtis 1 Pterguim 1 Photophobia 1 Decreased sweating 1 | Conjunctivitis 0 Pterguim 0 Photophobia 0 Decreased sweating 0
| | | | Tiredness 0 Dry eyes 2 | Tiredness 2 Dry eyes 0
| | Post-therapy back total lesions change | Long (24) | Decreased 5 No change 8 Ok new lesion 2 | Decreased 0 No change 10 Ok new lesion 5
| | Post-therapy chest total lesion change | Long (24) | Decreased rate 2 No change 4 Ok rate at baseline 9 | Decreased rate 0 No change 3 Ok rate at baseline 12
| K.03.01 | | | Vitamin A | Placebo
12 ↑ Parallel N=80 | | Overall change/dermatologist | Mid (12) | Improved 10 No change 18 Worse 2 | Improved 11 No change 9 Worse 21
| | Overall change/generalist | Mid (12) | Improved 24 No change 5 Worse 1 | Improved 22 No change 8 Worse 1

TRIAL:↑↓ -presence of positive or negative methodological features (see Summary Table). “Mild/mod,” etc., -our assessment of entry severity of study patients. “P”- to parallel study, “S”-split face design. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table M1. Articles/arms for class ANTI-ANDROGEN

Comp-Trial | | TARGET | | HEADING | | COMPARATOR | | Outcome Table(s)
Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment
M.01.01 | 141 | Cyproterone | 20 mg topical qhs. | Applied with calibrated pipette. | Vehicle | No dose information. | | Continuous
M.01.02 | 245 | Ethinyl estradiol Cyproterone | 0.05 mg oral qd. 2 mg oral qd. | Combination pill is taken qd x 21 days, then 7 days off. | Minocycline hydrochloride | 50 mg oral bid. | | Continuous Discrete
M.01.03 | 137 | Placebo Cyproterone Ethinyl estradiol | No dose information. 2 mg oral qd. 0.05 mg oral qd. | Cyproterone + ee: 21 days on then 7 days off. | Tetracycline Placebo | 500 mg oral (28d) No dose information. | | Continuous Discrete
M.01.04 | 141 | Cyproterone Ethinyl estradiol | 2 mg oral qd. 0.035 mg oral qd. | OCP schedule: 2ld pills; 7d placebo. | Cyproterone | 20 mg topical qhs. | Applied with calibrated pipette. | Continuous
M.01.05 | 48 | Ethinyl estradiol Cyproterone | 0.05 mg oral qd. 2 mg oral qd. | Frequency was not explicitly specified but presumably was qid. | Ethinyl estradiol Cyproterone | 0.035 mg oral qd. 2 mg oral qd. | | Continuous Discrete
| | Ethinyl estradiol Cyproterone | 0.05 mg oral qd. 2 mg oral qd. | Frequency was not explicitly specified but presumably was qid. | Ethinyl estradiol Levonorgestrel | 0.03 mg oral qd. 150 mg oral qd. | | Continuous Discrete
| 66 | Ethinyl estradiol Cyproterone | 0.05 mg oral qd. 2 mg oral qd. | | Ethinyl estradiol Cyproterone | 0.035 mg oral qd. 2 mg oral qd. | | Continuous Discrete
| 117 | Ethinyl estradiol Cyproterone | 0.05 mg oral qd. 2 mg oral qd. | Cycle 21 days on treatment and 7 days no treatment; treatment began day 5 of menstrual cycle. | Ethinyl estradiol Cyproterone | 0.035 mg oral qd. 2 mg oral qd. | Cycle 21 days on treatment and 7 days no treatment; treatment began day 5 of menstrual cycle. | Continuous
M.01.06 | 237 | Ethinyl estradiol Cyproterone | 0.05 mg oral qd. 2 mg oral qd. | Combo taken from days 5-25 of the cycle. | Ethinyl estradiol Cyproterone | 0.05 mg oral qd. 0.05 mg oral qd. | Cyproterone was taken from days 5-14 of cycle inclusive ee was taken from days 5-25 of cycle inclusive. Followed reversed sequential regime of Hammmerstein et al (1975). | Continuous Discrete
M.01.07 | 55 | Ethinyl estradiol Desogestrel | 0.03 mg oral qd. 150 mg oral qd. | 21 days tablets; 7 days no tablets. | Ethinyl estradiol Cyproterone | 0.05 mg oral qd. 2 mg oral qd. | 21 days tablets; 7 days no tablets. | Continuous Discrete
| 87 | Ethinyl estradiol Cyproterone | 35 mg oral qd. 2 mg oral qd. | 21 days: 2.0 mg cyproterone + 35 mg ee; 7 days: no treatment. | Ethinyl estradiol Desogestrel | 0.035 mg oral qd. No dose information. | 7 days: 0.025 mg desogestrol + 0.040 mg ee; 15 days: 0.125 mg desogestrol + 0.030 mg ee; 6 days: no treatment. | Continuous Discrete
| 103 | Ethinyl estradiol Cyproterone | 0.035 mg oral qd. 2 mg oral qd. | 618 cycles; started day 1 of menstrual cycle; no definition of cycle. | Desogestrel Ethinyl estradiol | 0.15 mg oral qd. 0.03 mg oral qd. | 618 cycles; started day 1 of menstrual cycle; no definition of cycle. | Discrete
M.01.08 | 48 | Ethinyl estradiol Cyproterone | 0.035 mg oral qd. 2 mg oral qd. | | Ethinyl estradiol Levonorgestrel | 0.03 mg oral qd. 150 mg oral qd. | | Continuous Discrete
M.01.09 | 237 | Ethinyl estradiol Cyproterone | 0.05 mg oral qd. 0.05 mg oral qd. | Cyproterone was taken from days 5-14 of cycle inclusive ee was taken from days 5-25 of cycle inclusive. Followed reversed sequential regime of Hammmerstein et al (1975). | Ethinyl estradiol Placebo Norethisterone | 0.05 mg oral qd. No dose information. 1 mg oral qd. | Placebo to resemble (cpa 50 mg tablets); combo preparation of norethisterone acetate 1mg + ee 50 mg taken days (5-25) of the cycle -inclusive and placebo taken from days 5-14 inclusive. | Continuous Discrete
M.02.01 | 225 | Desogestrel Ethinyl estradiol | 0.15 mg oral qd. 0.03 mg oral qd. | Qd x 9 cycles of 21 days each, with a 7 day treatment. | Gestodene Ethinyl estradiol | 0.075 mg oral qd. 0.03 mg oral qd. | Qd x 9 cycles of 21 days each, with a 7 day treatment. | Continuous Discrete
M.02.02 | 263 | Ethinyl estradiol Desogestrel | 0.03 mg oral () 0.15 mg oral () | | Ethinyl estradiol Levonorgestrel | 0.03 mg oral () 0.15 mg oral () | | Discrete
| 264 | Ethinyl estradiol Desogestrel | 0.03 mg oral qd. 0.15 mg oral qd. | | Ethinyl estradiol Levonorgestrel | 0.03 mg oral qd. 0.15 mg oral qd. | | Continuous Discrete
M.03.01 | 132 | Spironolactone | 100 mg oral (can't say) | | Placebo | No dose information. | | (M)
| 249 | Spironolactone | 200 mg oral qd. | Following by placebo in second half of study. | Placebo | No dose information. | Followed by spironolactone in second half of study. | Continuous Discrete
M.04.01 | 2 | Delta-0.2%-chlormadione | 0.2 % topical bid. | | Vehicle | No dose information. | | Discrete
M.04.02 | 2 | Delta-5%-chlormadione | 5 mg topical bid. | 1/4 inch of cream applied each application = 5 mg. | Vehicle | No dose information. | | Discrete
M.04.03 | 2 | Delta-0.2%-chlormadione | 0.2 % topical bid. | | Delta-5%-chlormadione | 5 mg topical bid. | 1/4 inch of cream applied each application = 5 mg. | Discrete
M.04.04 | 19 | 16-epiestriol-3-allyl ether | 15 mg oral (qd for 4 weeks, bid for 4 weeks, tid for 4 weeks) | Synthetic estrogen. Topical - varied. | Placebo | 15 mg oral (qd for 4 weeks, bid for 4 weeks, tid for 4 weeks) | Topical - varied. | Discrete
M.04.05 | 295 | Epiestriol | 2.5 mg/g topical qd. | | Vehicle | No dose information. | | Discrete
M.04.06 | 213 | Inocoterone acetate | 10 % topical bid. | Generic soap and shampoo. | Vehicle | No dose information. | Generic soap and shampoo. | Continuous Discrete
M.04.09 | 218 | Inactive drug Norgestimate Ethinyl estradiol | No dose information. 0.18 mg oral qd. 0.035 mg oral qd. | 21 days of active treatment followed by 7 days of inactive drug: 0.0180 for 7 days; 0.215 for 7 days; 0.250 for 7 days; 0 for 7 days. | Placebo | No dose information. | Color-matched tablets. | Continuous Discrete
| 280 | Norgestimate Ethinyl estradiol | No dose information. 0.035 mg oral qd. | 180 mg 1-7 days; 215 mg 8-14 days; 250 mg 15-21 days. | Placebo | No dose information. | | Continuous Discrete
M.04.10 | 248 | Quinestradol | 1 mg oral qd. | | Placebo | No dose information. | Proprietary topical preparation containing mild antiseptic and peeling agents. | Continuous
M.04.11 | 271 | Serum gonadotrophin | 58 unit oral () | 100 u qd X 2w; then 50 u qd X 4 w; then 25 u qod x 6 w. light, Cetrimide^®^, ultra-violet tetracyline. | Placebo | 58 units oral qd. | Cetrimide^®^, ultra-violet light, tetracycline. | Discrete
N.06.01 | 156 | Cimetidine | 1.6 g oral (*) | 1.6 g per day in “divided dose” - doesn't say how many. | Cimetidine | 1.6 g oral (*) | 1.6 g per day in “divided dose” - doesn't say how many. | Continuous (M)

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table M2. CONTINUOUS outcomes for class ANTI-ANDROGEN

Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Target | | Comparator | | Between P-value
Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Data Type: Mean (SD) | Within P | Data Type: Mean (SD) | Within P | Between P-value
141 ↓ Parallel | N=45 Mild/mod | M.01.01 | Face severity (leeds) | Mid (8) | Cyproterone (topical) Measure: 1 (0.02) | | Vehicle Measure: 1 (0.08) | | NS*
| | | Face severity change (leeds) | Mid (12) | Measure: −1 (0.11) | | Measure: 0 (0.04) | | 0.05
| | | Total lesions (count) Count location: Excluded nose. Baseline counts: 36 (Target)/38 (Comparator) | Mid (12) | Percent Change*: −51 | | Percent Change*: −28 | | NS*
| | | Total lesions change (count) | Mid (12) | Percent change*: −75 | | Percent change*: −40 | | 0.05
245 ↓ Parallel | N=98 Mild/mod | M.01.02 | Comedones (count/median) | Mid (8) | Cyproterone + ethinyl estradiol Measure: 8 | | Minocycline hydrochloride Measure: 10
| | | Papules (count/median) | Mid (8) | Measure: 16 | | Measure: 14
| | | Pustules (count/median) | Mid (8) | Measure: 8 | | Measure: 7
| | | Comedones (count/max range) | Long (24) | Measure: 63 | .01 | Measure: 327 | .01
| | | Comedones (count/median) | Long (24) | Measure: 5 | .01 | Measure: 4 | .01
| | | Papules (count/max) | Long (24) | Measure: 6 | .01 | Measure: 7 | .01
| | | Papules range (count/max) | Long (24) | Measure: 81 | | Measure: 307
| | | Pustules (count/max) | Long (24) | Measure: 48 | | Measure: 189
| | | Pustules (count/median) | Long (24) | Measure: 2 | .01 | Measure: 2 | .01
M.01.03 | | | | Cyproterone + ethinyl estradiol + placebo | | | Tetracycline + placebo
137 ↑ Parallel | N=92 | | Face severity change (leeds %) | Short (6) | Measure: −29 | .001 | Measure: −25 | .001
| | | Inflammatory change (%) | Mid (8) | Percent change: −20 | .05 | Percent change: −9 | .05
| | | Non-inflammatory change (%) | Mid (8) | Percent change: −37 | .01 | Percent change: −18 | .05
| | | Total severity change (leeds %) | Mid (8) | Measure: −20 | .01 | Measure: −22 | .05
| | | Face severity change (leeds %) | Long (24) | Measure: −71 | .001 | Measure: −72 | .001
137 ↑ Parallel | N=92 | | Inflammatory change (%) Between P-value: vs tetracucline alone or combined. | Long (24) | Percent change: −72 | .001 | Percent change: −50 | .001 | NS
| | | Non-inflammatory change (%) | Long (24) | Percent change: −76 | NS | Percent change: −63 | .05
| | | Total severity change (leeds %) Between P-value: vs tetracucline alone or combined. | Long (24) | Measure: −75 | .001 | Measure: −68 | .001 | NS
| | | Post-therapy facial severity change (leeds %) | Long (32) | Measure: −72 | .001 | Measure: −55 | .01
| | | Post-therapy inflammatory change (%) Between P-value: vs cyp/ee + tet. | Long (32) | Percent change: −79 | .001 | Percent change: −60 | .05 | NS
| | | Post-therapy non-inflammatory change (%) | Long (32) | Percent change: −81 | .01 | Percent change: −66 | .05
| | | Post-therapy total severity change (leeds %) | Long (32) | Measure: −75 | .001 | Measure: −55 | NS
141 ↓ Parallel | N=45 Mild/mod | M.01.04 | Face severity (leeds) | Mid (8) | Cyproterone + ethinyl estradiol (0.035) Measure: 1 (0.02) | | Cyproterone (topical) Measure: 1 (0.02) | | NS*
| | | Total lesions (count) Baseline counts: 45 (Target)/36 (Comparator) | Mid (8) | Percent Change*: −45 | | Percent Change*: −51 | | NS*
| | | Face severity change (leeds) | Mid (12) | Measure: −1 (0.12) | | Measure: −1 (0.11) | | 0.05
| | | Total lesions change (count) Count location: Excluded nose. Baseline counts: 45 (Target)/36 (Comparator) | Mid (12) | Percent change*: −66 | | Percent change*: −75 | | 0.05
48 ↑ Parallel | N=133 | M.01.05 | Total lesions change (%) Between P-value: vs Levonogestrel. | Long (16) | Cyproterone + ethinyl estradiol (0.05) Percent change: −51 (52.) | | Cyproterone + ethinyl estradiol (0.035) Percent change: −61 (31.) | | 0.05
117 ↓ Parallel | N=73 Mod/sev | | Comedones severity (cook) Count location: Face. | Long (24) | Measure: 1 | .01 | Measure: 2 | .01 | NS
| | | Macules score (cook) | Long (24) | Measure: 2 | .01 | Measure: 2 | .01 | NS
117 ↓ Parallel | N=73 Mod/sev | | Papules score (cook) Count location: Face. | Long (24) | Measure: 2 | .01 | Measure: 2 | .01 | NS
| | | Severity (cook) | Long (24) | Measure: 2 | .01 | Measure: 2 | .01 | NS
48 ↑ Parallel | N=133 | | Total lesions change (%) Between P-value: vs Levonogestrel. | Long (24) | Percent change: −70 (36.) | | Percent change: −72 (27.) | | 0.001
66 | N=96 | | Severity change/patient (vas) | Long (36) | Measure: 5 (2.7) | .001 | Measure: 5 (2.4) | .001 | NS
117 ↓ Parallel | N=73 Mod/sev | | Comedones severity (cook) Count location: Face. | Long (48) | Measure: 1 | .01 | Measure: 1 | .01 | NS
| | | Macules score (cook) | Long (48) | Measure: 1 | .01 | Measure: 1 | .01 | NS
| | | Papules time (cook) | Long (48) | Measure: 1 | .01 | Measure: 1 | .01 | NS
| | | Severity (cook) | Long (48) | Measure: 1 | .01 | Measure: 1 | .01 | NS
48 ↑ Parallel | N=133 | M.01.05 | Total lesions change (%) Between P-value: vs Levonogestrel. | Long (16) | Cyproterone + ethinyl estradiol (0.05) Percent change: −51 (52.) | | Levonorgestrel + ethinyl estradiol (0.030) Percent change: −27 (52.) | | 0.05
| | | Total lesions change (%) | Long (24) | Percent change: −70 (36.) | | Percent change: −35 (60.) | | 0.001
M.01.06 | | | | Cyproterone (2 mg) + ethinyl estradiol | | | Cyproterone (.05 mg) + ethinyl estradiol
237 Parallel | N=90 Mod/sev | | Face severity (leeds) | Mid (8) | Measure: 1 | .01 | Measure: 1 | .001
| | | Face severity/photo Between P-value: vs norethisterone. | Mid (8) | Measure: 1 | | Measure: 1 | | NS
| | | Macules (count) | Mid (8) | Raw count: 75 (66.) | | Percent Change*: 35 | | NS
| | | Papules (count) | Mid (8) | Raw count: 27 (37.) | NS | Percent Change*: −15 | NS | NS
| | | Total severity (leeds) Between P-value: vs norethisterone. | Mid (8) | Measure: 2 | .05 | Measure: 2 | .05 | 0.05
| | | Face severity (leeds) | Long (26) | Measure: 1 | .001 | Measure: 0 | .001 | 0.001
| | | Face severity/photo | Long (26) | Measure: 1 | | Measure: 0 | | 0.001
237 Parallel | N=90 Mod/sev | | Nodules (count) Between P-value: “worse than cyproterone (50)” P.05. | Long (26) | Raw count: 39 (64.) | | Raw count: 21 (45.) | | NS*
| | | Papules (count) | Long (26) | Raw count: 15 (18.) | .005 | Percent Change*: −79 | .001 | NS*
| | | Total severity (leeds) Between P-value: vs norethisterone. | Long (26) | Measure: 1 | .001 | Measure: 1 | .001 | 0.05
87 ↓ Parallel | N=183 Mild | M.01.07 | Comedones change (count/median) | Long (16) | Cyproterone + ethinyl estradiol (0.035) Measure: −6 | | Desogestrel + ethinyl estradiol Measure: −3
| | | Papules change (count/median) | Long (16) | Measure: −5 | | Measure: −5
| | | Pustules change (count/median) | Long (16) | Measure: −3 | | Measure: −2
| | | Severity (leeds) | Long (16) | Measure: 1 (0.53) | | Measure: 0 (0.42) | | NS*
| | | Severity change (dieben/median) | Long (16) | Measure: 0 (0.53) | | Measure: 0 (0.45) | | NS*
M.01.07 | | | | Desogestrel + ethinyl estradiol | | | Cyproterone + ethinyl estradiol (.05)
55 ↓ Parallel | N=66 | | Severity [center a] (charoenvisal) Count location: Face. | Short (4) | Measure: 2 | NS | Measure: 2 | NS | NS
| | | Severity [center b] (charoenvisal) | Short (4) | Measure: 2 | NS | Measure: 2 | NS | NS
| | | Severity [center a] (charoenvisal) | Mid (12) | Measure: 1 | NS | Measure: 1 | .05 | NS
| | | Severity [center b] (charoenvisal) | Mid (12) | Measure: 2 | .05 | Measure: 2 | NS | NS
| | | Severity [center a] (charoenvisal) | Long (24) | Measure: 2 | NS | Measure: 1 | .05 | 0.05
| | | Severity [center b] (charoenvisal) | Long (24) | Measure: 1 | .01 | Measure: 1 | .001 | NS
48 ↑ Parallel | N=133 | M.01.08 | Total lesions change (%) | Long (16) | Cyproterone + ethinyl estradiol (0.035) Percent change: −61 (31.) | | Levonorgestrel + ethinyl estradiol (0.030) Percent change: −27 (52.) | | NS
| | | Total lesions change (%) Between P-value: vs Levonogestrel. | Long (24) | Percent change: −72 (27.) | | Percent change: −35 (60.) | | 0.001
M.01.09 | | | | Cyproterone (.05 mg) + ethinyl estradiol | | | Norethisterone + placebo + ethinyl estradiol
237 Parallel | N=90 Mod/sev | | Face severity (leeds) Between P-value: vs norethisterone. | Mid (8) | Measure: 1 | .001 | Measure: 1 | .001 | 0.05
| | | Face severity/photo | Mid (8) | Measure: 1 | | Measure: 1 | | 0.05
| | | Macules (count) Baseline counts: 43 (Target)/(Comparator) | Mid (8) | Percent Change*: 35 | | Raw count: 56 (64.) | | NS
| | | Papules (count) Baseline counts: 27 (Target)/30 (Comparator) | Mid (8) | Percent Change*: −15 | NS | Percent Change*: −10 | NS | NS
| | | Total severity (leeds) Between P-value: vs norethisterone. | Mid (8) | Measure: 2 | .05 | Measure: 3 | NS | 0.01
| | | Face severity (leeds) | Long (26) | Measure: 0 | .001 | Measure: 1 | .001 | 0.001
| | | Face severity/photo | Long (26) | Measure: 0 | | Measure: 1 | | 0.001
| | | Nodules (count) | Long (26) | Raw count: 21 (45.) | | Percent Change*: 26 | | NS*
| | | Papules (count) Baseline counts: 27 (Target)/30 (Comparator) | Long (26) | Percent Change*: −79 | .001 | Percent Change*: −34 | NS | NS*
| | | Total severity (leeds) Between P-value: vs norethisterone. | Long (26) | Measure: 1 | .001 | Measure: 2 | .05 | 0.01
225 ↓ Parallel | N=24 Mild/mod | M.02.01 | Severity/arm (pillsbury) Count location: Each side of face. | Mid (12) | Desogestrel + ethinyl estradiol Measure: 2 | | Gestodene + ethinyl estradiol Measure: 2
| | | Severity/arm (pillsbury) | Long (36) | Measure: 1 | .05 | Measure: 1 | .02
M.02.02 | | | | Desogestrel + ethinyl estradiol | | | Levonorgestrel + ethinyl estradiol
264 ↑ Parallel | N=33 Mild/mod | | Severity (allen-smith) | Long (24) | Measure: 1 (0.55) | .001 | Measure: 1 (0.56) | .01 | 0.05
249 ↑ Cross-over | N=58 Mild/mod | M.03.01 | Total lesions [phase i+phase ii] (count) Baseline counts: 38 (Target)/24 (Comparator) | Mid (12) | Spironolactone Percent Change*: −66 | | Placebo Percent Change*: 05 | | 0.001
213 ↑ Parallel | N=153 Mod | M.04.06 | Comedones (count) Baseline counts: 22 (Target)/26 (Comparator) | Short (4) | Inocoterone acetate Percent Change*: 05 | | Vehicle Percent Change*: −19 | | NS
| | | Inflammatory (count) Baseline counts: 26 (Target)/27 (Comparator) | Short (4) | Percent Change*: −15 | | Percent Change*: −11 | | NS
| | | Comedones (count) Baseline counts: 22 (Target)/26 (Comparator) | Mid (12) | Percent Change*: −09 | | Percent Change*: −12 | | NS
| | | Inflammatory (count) Baseline counts: 26 (Target)/27 (Comparator) | Mid (12) | Percent Change*: −23 | | Percent Change*: −15 | | 0.019
| | | Comedones (count) Baseline counts: 22 (Target)/26 (Comparator) | Long (16) | Percent Change*: −09 | | Percent Change*: −19 | | NS
| | | Inflammatory (count) Baseline counts: 26 (Target)/27 (Comparator) | Long (16) | Percent Change*: −31 | | Percent Change*: −15 | | 0.025
218 ↑ Parallel | N=257 Mod | M.04.09 | Total lesions change (%) | Mid (12) | Norgestimate + ethinyl estradiol + inactive drug Percent change: −33 | | Placebo Percent change: −22 | | NS
| | | Total lesions change (%) | Long (24) | Percent change: −53 (29.9) | | Percent change: −27 (43.7) | | 0.0001
280 ↑ | N=250 | | Comedones change (count) Count location: Face. Baseline counts: 37 (Target)/38 (Comparator) | Long (26) | Percent change*: 40 | | Percent change*: 34 | | NS
218 ↑ Parallel | N=257 Mod | | Comedones change (count) Baseline counts: 35 (Target)/30 (Comparator) | Long (26) | Percent change*: 49 | | Percent change*: 22 | | 0.0003
| | | Inflammatory (count) Baseline counts: 19 (Target)/20 (Comparator) | Long (26) | Percent Change*: −39 | | Percent Change*: −62 | | 0.0001
280 ↑ | N=250 | | Inflammatory change (count) Baseline counts: 19 (Target)/19 (Comparator) | Long (26) | Percent change*: 49 | | Percent change*: 35 | | 0.02
218 ↑ | N=257 | | Nodules change (count) Baseline counts: 0 (Target)/0 (Comparator) | Long (26) | Percent change*: 33 | | Percent change*: 00 | | NS
280 ↑ | N=250 | | Total lesions change (count) Count location: Face. Baseline counts: 56 (Target)/57 (Comparator) | Long (26) | Percent change*: 43 | | Percent change*: 34 | | NS
248 ↓ Parallel | N=60 Mild/mod | M.04.10 | Comedones (count) Count location: Left side. Baseline counts: 32 (Target)/28 (Comparator) | Mid (8) | Quinestradol Percent Change*: −50 | .01 | Placebo Percent Change*: −29 | NS | NS*
| | | Total lesions (count) Count location: Left side. | Mid (8) | Raw count: 22 (15.6) | .001 | Raw count: 27 (18.3) | .01 | NS*

TRIAL: ↑↓ - presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., - our assessment of entry severity of study patients. “P”- parallel study, “S”- split face design. TARGET and COMPARATOR: “Percent change”- an outcome derived from individual final and baseline measures; “Percent change*”- we calculated a group-based percentage change; “Change” - raw difference from baseline; “Change*” - calculated change; “Measure” - an outcome measure with no baseline comparison. SD: standard deviation. WITHIN P: P-value with respect to baseline in one arm. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table M3: DISCRETE outcomes for class ANTI-ANDROGEN

Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Treatment | Comparator | Between P-value
Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Attribute: Number of patients | Attribute: Number of patients | Between P-value
245 ↓ Parallel Mild/mod N=98 | M.01.02 | GI+other side effects | | Cyproterone + ethinyl estradiol Heartburn/ depression 0 Diarrhea 0 Nausea/vomiting/giddness 2 Bleeding problems 4 | Minocycline hydrochloride Heartburn/ depression 4 Diarrhea 4 Nausea/vomiting/giddness 3 Bleeding problems 1 | NS
| | Gyn side effects | | Headaches 4 White vaginal discharge 1 Weight gain 5 Painful/swollen breasts 3 Vaginal irritation 0 | Headaches 3 White vaginal discharge 0 Weight gain 1 Painful/swollen breasts 0 Vaginal irritation 1 | NS
| | Skin side effects | | Headaches/giddness/fluid retention 1 Dry skin 1 Spider nevus on nose 1 Hair falling out 0 Itching 0 | Headaches/giddiness/fluid retention 0 Dry skin 0 Spider nevus on nose 0 Hair falling out 1 Itching 1 | NS
| | Overall change/patient | Long (24) | Anxiety, depression Some improvement 36 Complete improvement 7 Other 6 | Anxiety, depression Some improvement 34 Complete improvement 8 Other 7 | NS
137 ↑ Parallel N=92 | M.01.03 | Systemic reactions | Long (24) | Cyproterone + ethinyl estradiol + placebo Chest pain 0 Headache 0 Menstrual irregularity 0 Breast tenderness 0 | Tetracycline + placebo Chest pain 0 Headache 0 Menstrual irregularity 0 Breast tenderness 0
| | | | Hypertension 1 Dysmenorrhoea 1 | Hypertension 0 Dysmenorrhoea 0
48 ↑ Parallel N=133 | M.01.05 | Discontinuation due to side effects | | Cyproterone + ethinyl estradiol (0.05) Discontinuation 5 | Levonorgestrel + ethinyl estradiol (0.030) Discontinuation 6
48 ↑ Parallel N=133 | | Total lesions change Between P-value: vs levonorgestrel | Long (24) | > 75% reduction 30 No change or worse 2 Else (total-1-2) 13 | >75% reduction 9 No change or worse 6 Else (total-1-2) 21 | 0.001
103 Parallel N=162 | M.01.07 | Back improvement | Mid (12) | Cyproterone + ethinyl estradiol (0.035) Yes 41 No 38 | Desogestrel + ethinyl estradiol Yes 38 No 45 | NS
| | Chest improvement | Mid (12) | Yes 43 No 36 | Yes 42 No 41 | NS
| | Complete healing | Mid (12) | Yes 28 No 51 | Yes 20 No 63
| | Face improvement | Mid (12) | Yes 46 No 33 | Yes 32 No 51 | 0.05
| | Back improvement | Long (32) | Yes 66 No 13 | Yes 68 No 15 | NS
| | Chest improvement | Long (32) | Yes 68 No 11 | Yes 65 No 18 | NS
| | Complete healing | Long (32) | Yes 46 No 33 | Yes 62 No 21
| | Face improvement | Long (32) | Yes 64 No 15 | Yes 52 No 31 | 0.05
| | Side effects | Long (32) | Headache 75 Reduced libido 5 Breast tenderness 19 Nervousness 21 | Headache 76 Reduced libido 29 Breast tenderness 58 Nervousness 48 | 0.05
| | | | Depression 9 Edema 29 | Depression 45 Edema 22
48 ↑ Parallel N=133 | M.01.08 | Discontinuation due to side effects | | Cyproterone + ethinyl estradiol (0.035) Discontinuation 6 | Levonorgestrel + ethinyl estradiol (0.030) Discontinuation 6
48 ↑ Parallel N=133 | | Total lesions change Between P-value: vs levonorgestrel | Long (24) | >75% reduction 27 No change or worse 2 Else (total-1-2) 15 | >75% reduction 9 No change or worse 6 Else (total-1-2) 21 | 0.001
237 Parallel Mod/sev N=90 | M.01.09 | Systemic reactions I > once | Long (26) | Cyproterone (.05 mg) + ethinyl estradiol Tiredness/lassitude 3 Loss of libido 1 Headaches 3 Dizziness/ giddiness 0 | Norethisterone + placebo + ethinyl estradiol Tiredness/lassitude 4 Loss of libido 0 Headaches 3 Dizziness/ giddiness 1
| | Systemic reactions I once only | Long (26) | Breast soreness 2 Urinary urgency 1 depression 1 Nausea/vomiting 2 Tiredness/lassitude 1 Loss of libido 1 Headaches 4 Dizziness/giddiness 4 | Breast soreness 2 Urinary urgency 0 Depression 1 Nausea/vomiting 2 Tiredness/lassitude 1 Loss of libido 1 Headaches 2 Dizziness/giddiness 3
| | Systemic reactions II > once | Long (26) | Breast soreness 4 Urinary urgency 3 depression 3 Nausea/vomiting 2 Abnormal uterine bleeding 1 Aching legs 0 Consipation 0 Abdominal pain 0 | Breast soreness 3 Urinary urgency 3 Depression 3 Nausea/vomiting 6 Abnormal uterine bleeding 0 Aching legs 0 Consipation 0 Abdominal pain 0
| | Systemic reactions II once only | Long (26) | Benign breast tomor 0 Vaginal discharge 0 Abnormal uterine bleeding 4 Aching legs 3 Constipation 0 Abdominal pain 0 | Benign breast tomor 0 Vaginal discharge 0 Abnormal uterine bleeding 3 Aching legs 1 Constipation 3 Abdominal pain 0
| | | | Benign breast tumor 0 Vaginal discharge 0 | Benign breast tumor 0 Vaginal discharge 0
225 ↓ Parallel Mild/mod N=24 | M.02.01 | Severity (pillsbury) | Mid (12) | Desogestrel + ethinyl estradiol Absent 0 Minimal 3 Minor 2 Mild 6 | Gestodene + ethinyl estradiol Absent 1 Minimal 1 Minor 2 Mild 4
| | Severity change (pillsbury) | Long (36) | Moderate 0 Absent 2 Minimal 8 Minor 1 Mild 0 | Moderate 0 Absent 3 Minimal 2 Minor 1 Mild 2
| | Systemic adverse effects | Long (36) | Moderate 0 Present 6 Absent 5 | Moderate 0 Present 4 Absent 4
263 Parallel N=54 | M.02.02 | Side effects | | Desogestrel + ethinyl estradiol Worse acne & drop out 2 Irregular bleed 2 | Levonorgestrel + ethinyl estradiol Worse acne & drop out 4 Irregular bleed 3
| | Severity change | Long (24) | Improved 9 No improvement 1 | Improved 5 No improvement 4 | 0.05
249 ↑ Cross-over Mild/mod N=58 | M.03.01 | Change (count) | Mid (12) | Spironolactone Improved 15 Unchanged 5 Worse 0 | Placebo Improved 4 Unchanged 9 Worse 7 | 0.001
| | Overall change/patient | Mid (12) | Proportion improved 18 Proportion unchanged 3 Proportion worse 0 | Proportion improved 5 Proportion unchanged 9 Proportion worse 7 | 0.001
| | Positive side effects | Mid (12) | Decreased oily skin 9 Breast enlargement 2 | Decreased oily skin 0 Breast enlargement 0
| | Severity/photo | Mid (12) | Improved 11 Unchanged 7 Worse 1 | Improved 4 Unchanged 12 Worse 3 | 0.02
249 ↑ Cross-over Mild/mod N=58 | | Side effects | Mid (12) | Menstrual irregularity 11 Severe nausea (drop out) 2 Nausea 1 Dizziness 1 | Menstrual irregularity 0 Severe nausea (drop out) 0 Nausea 0 Dizziness 0
2 ↑ Parallel split face N=20 | M.04.01 | Overall change/patient | Mid (7) | Delta-0.2%-chlormadione Change in acne 0 No change in acne 10 | Vehicle Change in acne 0 No change in acne 20
| | Overall change/physician | Mid (7) | Change in acne 0 No change in acne 10 | Change in acne 0 No change in acne 20
2 ↑ Parallel split face N=20 | M.04.02 | Overall change/patient | Mid (7) | Delta-5%-chlormadione Change in acne 0 No change in acne 10 | Vehicle Change in acne 0 No change in acne 20
| | Overall change/physician | Mid (7) | Change in acne 0 No change in acne 10 | Change in acne 0 No change in acne 20
2 ↑ Parallel split face N=20 | M.04.03 | Overall change/patient | Mid (7) | Delta-0.2%-chlormadione Change in acne 0 No change in acne 10 | Delta-5%-chlormadione Change in acne 0 No change in acne 10
| | Overall change/physician | Mid (7) | Change in acne 0 No change in acne 10 | Change in acne 0 No change in acne 10
19 Parallel N=134 | M.04.04 | Oiliness | Mid (12) | 16-epiestriol-3-allyl ether No change 30 Improved 19 Marked improvement 17 | Placebo No change 35 Improved 24 Marked improvement 9 | NS
| | Severity change | Mid (12) | No change 31 Improved 19 Marked improvement 16 | No change 34 Improved 26 Marked improvement 8 | NS
295 ↑ Parallel split face N=50 | M.04.05 | Inter-treatment severity change | Mid (12) | Epiestriol Better 9 Same 23 | Vehicle Better 23 Same 8
| | Overall change/physician | Mid (12) | Worse 7 Unchanged 18 Improved 19 | Worse 7 Unchanged 18 Improved 19
213 ↑ Parallel Mod N=153 | M.04.06 | Local adverse reactions | | Inocoterone acetate Burning 32 Stinging 18 Itching 10 Redness 19 | Vehicle Burning 24 Stinging 24 Itching 6 Redness 15 | NS
| | | | Peeling 27 | Peeling 12
218 ↑ Parallel Mod N=257 | M.04.09 | Overall change/investigator | Long (26) | Norgestimate + ethinyl estradiol + inactive drug Excellent 30 Good 28 Fair 16 No change 3 | Placebo Excellent 15 Good 24 Fair 14 No change 20 | 0.001
| | Overall change/patient | Long (26) | Worse 2 Much improved 34 Somewhat improved 39 Not improved 5 Worse 1 | Worse 8 Much improved 18 Somewhat improved 40 Not improved 19 Worse 4 | 0.001
280 ↑ Parallel Mod N=250 | | Adverse events | | Discontinued therapy 13 Other 113 | Discontinued therapy 5 Other 119
| | Overall change/investigator | Long (24) | Excellent 22 Good 32 Fair 16 No change 9 | Excellent 6 Good 25 Fair 19 No change 25 | 0.001
280 ↑ Parallel Mod N=250 | | Overall change/patient | Long (24) | Worse 5 Much improved 30 Somewhat improved 38 Not improved 10 Worse 5 | Worse 5 Much improved 10 Somewhat improved 28 Not improved 37 Worse 5 | 0.001
| | | | Much worse 0 | Much worse 0
271 ↑ Parallel Mild/mod/sev N=40 | M.04.11 | Overall change/patient with physician | Mid (12) | Serum gonadotrophin Improved 8 No change 9 Worse 2 | Placebo Improved 9 No change 9 Worse 3

TRIAL: ↑↓ -presence of positive or negative methodological features (see Summary Table). “Mild/mod,” etc., -our assessment of entry severity of study patients. “P”- to parallel study, “S”-split face design. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table N1. Articles/arms for class OTHER

Comp-Trial | | | TARGET | HEADING | | COMPARATOR | | Outcome Table(s)
Comp-Trial | | Treatment | Dose, route, frequency | Comments, ancillary treatment | Treatment | Dose, route, frequency | Comments, ancillary treatment | Outcome Table(s)
N.01.01 | 266 | Sunder vati | 500 mg oral tid. | Mild soap and water. | Placebo | 500 mg oral tid. | Mild soap and water. | Continuous (M)
N.01.02 | 325 | Gugulipid | 25 mg oral bid. | Gugulipid is standardized extract of Commiphora Mutrel, an Indian medicinal plant. | Tetracycline | 500 mg oral bid. | | Continuous Discrete
N.01.03 | 94 | Isolutrol | 0.15 % topical (can't say) | Frequency and dose unknown; deep sea shark liver oil. | Benzoyl peroxide | 5 % topical (can't say) | | Continuous Discrete
N.01.04 | 17 | Ocimum basilicum | No dose information. | Leaves crushed in palm and juice applied at night as thin smear over lesions. Mild soap in morning. | Tetracycline | 500 mg oral bid. | Dose maintained or reduced at 4 weeks depending on response. Sulfur lotion twice a day after washing with mild soap. | Discrete
N.01.05 | 18 | Tea tree oil | 5 % topical (can't say) | Melaleuca alternifolia. | Benzoyl peroxide | 5 % topical () | | Continuous Discrete
N.02.01 | 175 | Clobetasol propionate | No dose information. | To one side of the face. | Vehicle | No dose information. | | Continuous Discrete
N.02.03 | 288 | Hydrocortisone | 1 topical bid. | | Hydrocortisone Sulphur | 1 % topical bid. 4 % topical bid. | | Discrete (M)
N.02.04 | 228 | Methylprednisolone Neomycin | 2.5 % topical bid. 2.5 % topical bid. | | Vehicle | No dose information. | | Discrete
N.02.05 | 102 | Sulphur Neomycin Methylprednisol | 5 % topical (can't say) 0.25 % topical (can't say) 0.25 % topical (can't say) | | Vehicle | No dose information. | | Discrete
| 346 | Aluminum chlorhydroxide | 10 % topical qd. | | Placebo | No dose information | Vehicle for Neo-Medrol®. | Discrete
| | Sulfur Methylprednisolone Neomycin | 5 % topical qd. 0.25 % topical qd. 0.25 % topical qd. | | | | distinguishable from active drug.
N.02.06 | 228 | Methylprednisolone Neomycin | 2.5 % topical bid. 2.5 % topical bid. | | Aluminum chlorhydroxide | 50 % topical bid. 100 % topical bid. | Modified placebo. | Discrete
| 347 | Aluminum chlorhydroxide sulfur Methylprednisol Neomycin | 10 % topical qd. 0.25 % topical qd. 0.25 % topical qd. 0.25 % topical qd. | | Sulfur | 5 % topical qd. | Physically indistinguishable from Neo-Medrol®. | Discrete
N.03.01 | 189 | Gamma-globulin | 2 cc other (q 2 weeks) | Usual therapeutic measures. | Placebo | 2 cc other (q 2 weeks) | Colored to look like gamma globulin. | Discrete
N.03.02 | 15 | Unfractionated human dialyzable transfer factor | No dose information. | preparation of Tfd: human leucocyte dialysate was prepared from a pool of citrated buffy coats obtained from the Finnish Red Cross Blood Transfusion Service and fractionated on Sephadex® G-10 as previously described (Ashorn, R. Acta. Pathol. Microbiol Scand ICI 1982; 90: 331-7). Soap/low pH cleanser (average), and, if necessary, a cream containing salicylic acid and sulfur. | Fractionated human dialyzable transfer factor | No dose information | preparation of Tfd: human leucocyte dialysate was prepared from a pool of citrated buffy coats obtained from the Finnish Red Cross Blood Transfusion Service and fractionated on Sephadex® G-10 as previously described (Ashorn, R. Acta. Pathol. Microbiol Scand ICI 1982; 90: 331-7). Soap/low pH cleanser (average), and, if necessary, a cream containing salicylic acid and sulfur. | Discrete
N.03.03 | 222 | Staphylococcaltoxoid | 0.5 ml other (q 4 days) | .1 ml, .2 ml, .4 ml, .8 ml & 1.0 ml q 4 days. Soft soap, discretion, clean nails. | Vehicle | 0.5 cc other (q 4 days) | Soft soap, dietary discretion, clean nails. | Discrete
N.04.01 | 297 | Hydrocortisone Chloramphenico | 4 % topical bid. 4 % topical bid. | | Vehicle | No dose information. | | Discrete
N.04.02 | 224 | Buttoxethyl nicotinate Hydrocortisone Chloramphenicol Sulphur | No dose information. No dose information. No dose information. No dose information. | Normal skin toilet. | Vehicle | No dose information | | Continuous Discrete
N.04.03 | 142 | Hydrocortisone Sulphur Chloramphenicol | 4 % topical qhs. 32 % topical qhs. 4 % topical qhs. | Normal skin toilet. | Sulphur Chloramphenicol | 32 % topical qhs. 4 % topical qhs. | Normal skin toilet. | Continuous Discrete
N.04.04 | 115 | Sulphur Hydrocortisone Chloramphenicol | 32 % topical qhs. 4 % topical qhs. 4 % topical qhs. | Bid for first 4 days. | Sulphur Hydrocortisone | 32 % topical qhs. 4 % topical qhs. | Bid for first 4 days. | Continuous Discrete
N.04.05 | 75 | Sulphur Hydrocortisone Chloramphenicol | No dose information. No dose information. No dose information. | | Benzoyl peroxide | 5 % topical bid. | Frequency qd for 1 week then bid. | Continuous Discrete
N.05.01 | 138 | Grenz rays | 1600 rad other (tiw) | 100 rad 3 times a week until dose achieve. | Placebo | No dose information | Same set-up as Grenz arm, but with lead plate blocking radiation. | Discrete
| 139 | Grenz rays | 2400 rad topical (tiw) | 1600 rads initially, 4-8 week pause, then 800 rads. | Placebo | No dose information. | Same set-up as Grenz arm, but with lead plate blocking radiation. | Discrete
| 179 | Grenz rays | 1200 rad other qd. | 10 kv irradiation frequency 100 rad qd x 6 then 100 rad or 300 rad 9 week x 4. | Placebo | No dose information | | Discrete
N.05.01 | 180 | Grenz rays | 1200 rad other qd. | 50k irritation frequency 100 rad qd x 6 then 100 rad qwh x 6 or 300 rad 9 weeks x 4. | Placebo | No dose information | | Discrete
| 350 | Grenz rays | 200 rads other (monthly) | | Hexachlorophene Placebo | No dose information No dose information | | (M)
N.05.02 | 215 | Comedone extraction | No dose information. | Only right side treated. Some on oral antibiotics or Vitamin A. | Comedone extraction | No dose information | Only right side treated. Some on oral antibiotics or Vitamin A. | Discrete
| 216 | Comedone extraction | No dose information. | Only right side treated. Some on oral antibiotics or Vitamin A. | Untreated | No dose information | | Discrete
N.05.03 | 31 | | | EMLA topical anaesthetic 90 min prior to treatment. 4 patients tab oral anti-bacterial.. | Tretinoin | 0.025 % topical bid. | Treatment frequency varied between qd and bid, depending on patient's tolerance. 4 patients oral anti-bacterial.. | Continuous Discrete
N.05.04 | 32 | | | No topical anaesthetic.. | | | Topical anesthesia.. | Continuous
N.06.02 | 109 | Benzoyl peroxide | No dose information. | Signed a commitment to medications use and a chance to win $1 for every self monitoring card returned. | Benzoyl peroxide | No dose information | Asked to keep a record of use of the benzoyl peroxide. | Continuous (M)
N.06.03 | 172 | Erythromycin Benzoyl peroxide Relaxation-imagery | No dose information. No dose information. No dose information. | The first two sessions were biofeedback-assisted relaxation training. The third and fourth were biofeedback-assisted cue-controlled relaxation training. Session 5 though 12 were biofeedback assisted cue-controlled relaxation and guided cognitive imagery training.. Topical benzoyl peroxide and sulfur lotion, topical erythromycin ointment, and attendance at the clinic for lesion extraction.. | Erythromycin Benzoyl peroxide | No dose information No dose information | No treatment other than standard care at the clinic was administered in this group. This arm was “constructed” retrospectively and were not directly involved in the study.. Topical benzoyl peroxide and sulfur lotion, topical erythromycin ointment, and attendance at the clinic for lesion extraction.. | Continuous
N.06.04 | 178 | Hydrochlorthiazi | 50 mg oral bid. | Continued baseline ancillary treatment. | Vehicle | No dose information. | Continued baseline ancillary treatment. | Discrete
| 284 | Hydrochlorthiazide | 25 mg oral tid. | Soap washing tid; astringent; nightly use of a sulfur ointment. | Placebo | No dose information. | | Discrete
N.06.045 | 349 | Placebo Ibuprofen | No dose information. 600 mg oral qid. | Placebo of Tetracycline. | Placebo (ibuprofen) Placebo | No dose information. No dose information. | Tetragel® placebo + ibuprofen placebo. | Continuous (M) Discrete
N.06.05 | 110 | Tolbutamide | No dose information. | No change of topical therapy was made. | Vehicle | No dose information. | No change of topical therapy was made. | Discrete
N.07.01 | 64 | Zinc sulfate | 2 % topical tid. | | Vehicle | No dose information. | | Continuous
N.07.02 | 3 | Zinc sulfate | 220 mg oral bid. | After meals. | Placebo | No dose information | After meals. | Continuous Discrete
| 91 | Zinc gluconate | 200 mg oral qd. | 2 capsules 20 minutes before breakfast. | Placebo | No dose information. | 2 capsules 20 minutes before breakfast. | Continuous Discrete
| 133 | Zinc sulphur | 45 mg oral tid. | | Placebo | No dose information. | Identical in behavior to Zinc | Continuous Discrete
| 163 | Zinc sulfate | 0.2 g oral bid. | Dosage corresponds to 45 mg zn 2+. Local treatment with salicylic acid &/or liniment of sulfur corresponds to 45 mg zn 2+. | Placebo | No dose information | | Continuous Discrete
| 211 | Zinc sulfate | 600 mg oral qd. | | Placebo | | | Continuous
| 259 | Zinc sulfate monohydrate | 137 mg oral tid. | 4 week washout period with placebo. Bland soap, diet low in zinc. | Vehicle | No dose information. | 4 week washout period with placebo. Bland soap, diet low in zinc. | Continuous
| 336 | Zinc sulfate | 300 mg oral bid. | Dose of 300mg report represents weight of unknown amount of zinc plus lactose. | Vehicle | 300 mg oral bid. | | Continuous Discrete
| 341 | Zinc sulfate | 220 mg oral tid. | Usual soaps, OTC meds except benzoyl peroxide. | Placebo | No dose information. | | Continuous Discrete
| 342 | Zinc sulfate | 0.2 g oral tid. | Tablet dissolved in water three times a day after meals. | Vehicle | No dose information. | Tablet dissolved in water three times a day after meals; identical appearance and taste totreatment. | Continuous Discrete
N.07.03 | 74 | Zinc sulfate/citrate complex | No dose information. | No dose given: “1 three times daily”. | Tetracycline | 250 mg oral bid. | | Continuous
| 232 | Zinc sulfate | 0.2 gm oral tid. | | Oxytetracycline | 250 mg oral qd. | Tid 2 wks; bid 2 wks; qd 8wks. | Continuous
N.08.01 | 108 | Placebo (oral) Zinc acetate Erythromycin | No dose information. 1.2 % topical bid. 4 % topical bid. | | Placebo (oral) Placebo (topical) | No dose information. No dose information. | | Continuous (M)
| 301 | Zinc Erythromycin | 1.2 % topical bid. 4 % topical bid. | | Vehicle | No dose information. | Switched to erythro + zinc after 12 weeks. | Continuous Discrete
| 321 | Zinc acetate | 1.2 % topical bid. | Single product. | Vehicle | No dose information. | Vehicle diisopropyl sebacate 27%. | Continuous
N.08.02 | 28 | Zinc acetate Erythromycin | No dose information. No dose information. | Plain soap/cleansing. | Erythromycin | 4 % topical bid. | Plain soap/cleansing. | Continuous
| 147 | Zinc Erythromycin | No dose information. 4 % topical bid. | | Erythromycin | 2 % topical bid. | | Continuous Discrete
N.08.03 | 300 | Zinc Erythromycin | 1.2 % topical bid. 4 % topical bid. | | Clindamycin phosphate | 1 % topical bid. | | Continuous Discrete

“(M)” indicates that data are found on the Multi-Arm tables.

Evidence Table N2. CONTINUOUS outcomes for class OTHER

Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Target | | Comparator | | Between P-value
Trial # Method | | Comparison | Continuous Outcome Name (Units) Definition/Comments | Follow-up (wks) | Data Type: Mean (SD) | Within P | Data Type: Mean (SD) | Within P | Between P-value
325 ↑ Parallel | N=20 Sev | N.01.02 | Inflammatory change (%) | Mid (12) | Gugulipid Percent change: −68 | | Tetracycline Percent change: −65 | | NS
| | | Non-inflammatory change (%) | Mid (12) | Percent change: −12 | | Percent change: −11 | | NS
94 Parallel | N=70 Mild/mod | N.01.03 | Inflammatory (count)Count location: Face. Baseline counts: 24 (Target)/33 (Comparator) | Short (4) | Isolutrol Percent Change*: −16 | | Benzoyl peroxide Percent Change*: −34
| | | Non-inflammatory (count) Count location: Face. | Short (4) | Raw count: 20 | | Raw count: 17
| | | Inflammatory (count) Count location: Face. Baseline counts: 24 (Target)/33 (Comparator) | Mid (12) | Percent Change*: −33 | .06 | Percent Change*: −67 | .003
| | | Non-inflammatory (count) | Mid (12) | Raw count: 17 | .0002 | Raw count: 12 | .0001
18 ↑ Parallel | N=124 Mod | N.01.05 | Inflammatory (count) Count location: 3 + c face. Baseline counts: 35 (Target)/38 (Comparator) | Short (4) | Tea tree oil Percent Change*: −38 | | Benzoyl peroxide Percent Change*: −50 | | 0.05
| | | Non-inflammatory (count) Count location: 3 + c face. | Short (4) | Raw count: 32 | | Raw count: 25 | | NS
| | | Inflammatory (count) Count location: 3 + c face. Baseline counts: 35 (Target)/38 (Comparator) | Mid (12) | Percent Change*: −68 | .001 | Percent Change*: −47 | .001 | 0.001
| | | Non-inflammatory (count) Count location: 3 + c face. | Mid (12) | Raw count: 15 | .05 | Raw count: 16 | .01 | NS
175 ↑ Parallel Mod | N=11 split face | N.02.01 | Inflammatory (count) Baseline counts: 31 (Target)/33 (Comparator) | Short (3) | Clobetasol Percent Change*: 00 | | Vehicle Percent Change*: 00 | | NS
224 ↑ Cross-over Mild/mod/sev | N=120 | N.04.02 | Comedones reduction percentage change (%) | Short (5) | Hydrocortisone + buttoxethyl nicotinate + chloramp Percent change: −33 | | Vehicle Percent change: −93 | | NS
| | | Inter-group difference papule % change (%) | Mid (10) | Percent change: −52 | | Percent change: 65 | | 0.01
| | | Inter-group difference pustule % change (%) | Mid (10) | Percent change: 51 | | Percent change: 90 | | NS
142 Parallel | N=50 Mild/mod | N.04.03 | Severity (score) Count location: 3 in square. | Short (4) | Chloramphenicol + hydrocortisone + sulfur Measure: 26 | | Chloramphenicol + sulfur Measure: 33 | | NS
| | | Total lesions change (%) | Short (4) | Percent change: −71 | | Percent change: −57 | | NS
| | | Severity (score) | Mid (12) | Measure: 11 | | Measure: 8 | | NS
| | | Total lesions change (%) | Mid (12) | Percent change: −87 | | Percent change: −89 | | NS
115 ↑ Parallel | N=37 | N.04.04 | Severity change (fraser %) | Short (4) | Chloramphenicol + hydrocortisone + sulfur Measure: −48 | .001 | Hydrocortisone + sulfur Measure: −28 | .001 | 0.03
| | | Severity change (fraser %) | Mid (12) | Measure: −64 | .001 | Measure: −60 | .001 | NS
75 ↑ Parallel | N=48 Mod | N.04.05 | Inflammatory (count) Baseline counts: 21 (Target)/23 (Comparator) | Short (4) | Chloramphenicol + hydrocortisone + sulfur Percent Change*: −19 | NS | Benzoyl peroxide Percent Change*: −35 | .05 | NS*
| | | Non-inflammatory (count) Baseline counts: 40 (Target)/37 (Comparator) | Short (4) | Percent Change*: 00 | NS | Percent Change*: −30 | .01 | NS*
| | | Overall assessment/patient (vas) | Short (4) | Measure: 17 (3.) | .05 | Measure: 14 (4.) | .05 | NS*
| | | Severity (leeds) | Short (4) | Measure: 2 (0.2) | .01 | Measure: 2 (0.3) | .01 | NS*
75 ↑ Parallel | N=48 Mod | | Inflammatory (count) Baseline counts: 21 (Target)/23 (Comparator) | Mid (12) | Percent Change*: −38 | .01 | Percent Change*: −37 | .01 | NS*
| | | Non-inflammatory (count) Baseline counts: 40 (Target)/37 (Comparator) | Mid (12) | Percent Change*: −30 | NS | Percent Change*: −38 | .01 | NS*
| | | Overall assessment/patient (vas) | Mid (12) | Measure: 28 (5.) | .01 | Measure: 25 (8.) | .01 | NS*
| | | Severity (leeds) | Mid (12) | Measure: 1 (0.2) | .01 | Measure: 2 (0.2) | .01 | NS*
31 Parallel Mild | N=11 split face | N.05.03 | Closed comedone change (%) Count location: Symmetric area of face. | Short (4) | Fulguration Percent change: −92 (8.) | | Tretinoin Percent change: −10 (21.) | | 0.005
32 Parallel Mild | N=12 split face | N.05.04 | Large comedone change (%) Count location: Symmetric area of face. | Short (4) | Fulguration Percent change: −46 (23.) | | Electrocautery Percent change: −73 (12.) | | 0.025
| | | Small comedones change (%) | Short (4) | Percent change: −76 (13.) | | Percent change: −82 (11.) | | NS
64 Parallel | N=30 Mild/mod | N.07.01 | Irritation (score) | Short (6) | Zinc Measure: 2 | | Vehicle Measure: 1 | | 0.05
| | | Severity (michaelsson) Count location: Unspecified. | Short (6) | Measure: 98 | | Measure: 100 | | NS
| | | Irritation (score) | Mid (12) | Measure: 1 | | Measure: 1 | | 0.05
| | | Severity (michaelsson) Count location: Unspecified. | Mid (12) | Measure: 94 | | Measure: 98 | | NS
91 ↑ Parallel | N=66 Mod | N.07.02 | Inflammatory severity (dreno) Between P-value: inappropriate test. | Short (4) | Zinc Measure: 34 (14.8) | | Placebo Measure: 46 (28.7) | | NS
| | | Inflammatory severity (dreno) | Mid (8) | Measure: 27 (14.9) | | Measure: 47 (29.8) | | 0.02
341 ↑ ParallelMild/mod | N=52 Mild/mod | N.07.02 | Comedones (count) Count location: 2 cm worst. Baseline counts: 12 (Target)/13 (Comparator) | Short (6) | Zinc sulfate Percent Change*: −50 | | Placebo Percent Change*: −15 | | NS
| | | Cysts (count) Count location: Face & submandibular. Baselinecounts: 0 (Target)/0 (Comparator) | Short (6) | Percent Change*: 00 | | Percent Change*: −37 | | NS
| | | Papules (count) Count location: Face & submandibular. Baseline counts: 18 (Target)/21 (Comparator) | Short (6) | Percent Change*: −42 | | Percent Change*: −19 | | NS
| | | Pustules (count) Count location: Face & submandibular. Baseline counts: 9 (Target)/13 (Comparator) | Short (6) | Percent Change*: −49 | | Percent Change*: −52 | | NS
| | | Severity (michaelsson) | Short (6) | Measure: 21 | | Measure: 36 | | NS
211 Parallel | N=59 Mild/mod/sev | | Severity change (pillsbury %) | Short (6) | Measure: −33 (25.) | | Measure: −20 (25.) | | 0.007
341 ↑ Parallel | N=52 Mild/mod | | Comedones (count) Count location: 2 cm worst. Baseline counts: 12 (Target)/13 (Comparator) | Mid (12) | Percent Change*: −50 | | Percent Change*: −38 | | NS
| | | Cysts (count) Count location: Face & submandibular. Baseline counts: 0 (Target)/0 (Comparator) | Mid (12) | Percent Change*: 00 | | Percent Change*: −33 | | NS
| | | Papules (count) Count location: Face & submandibular. Baseline counts: 18 (Target)/21 (Comparator) | Mid (12) | Percent Change*: −48 | | Percent Change*: −37 | | NS
| | | Pustules (count) Count location: Face & submandibular. Baseline counts: 9 (Target)/13 (Comparator) | Mid (12) | Percent Change*: −37 | | Percent Change*: 02 | | NS
3 Parallel | N=42 | | Severity (agrawal) | Mid (12) | Measure: 43 (20.8) | | Measure: 44 (40.8) | | NS*
341 ↑ Parallel | N=52 Mild/mod | | Severity (michaelsson) | Mid (12) | Measure: 25 (21.) | | Measure: 44 (32.) | | NS
342 ↑ Parallel | N=39 Mod | N.07.02 | Infiltrates (count) Baseline counts: 6 (Target)/3 (Comparator) | Short (4) | Zinc sulfate Percent Change*: 06 | NS | Vehicle Percent Change*: 03 | NS | NS
| | | Papules (count) Baseline counts: 28 (Target)/41 (Comparator) | Short (4) | Percent Change*: −27 | .05 | Percent Change*: −34 | .05 | NS
| | | Pustules (count) Baseline counts: 10 (Target)/7 (Comparator) | Short (4) | Percent Change*: −42 | .05 | Percent Change*: −51 | .05 | NS
259 ↓ Parallel | N=30 Mild/mod | | Closed comedones (count) Baseline counts: 19 (Target)/39 (Comparator) | Short (6) | Percent Change*: −15 | NS | Percent Change*: −51 | NS | NS
336 ↑ Parallel | N=56 Mod | | Cysts (count) Count location: Well defined regions. Baseline counts: 1 (Target)/1 (Comparator) | Short (6) | Percent Change*: −04 | .001 | Percent Change*: −02 | NS | NS*
| | | Infiltrates (count) Count location: Well defined regions. Baseline counts: 2 (Target)/1 (Comparator) | Short (6) | Percent Change*: −13 | .001 | Percent Change*: 171 | .05 | NS*
259 ↓ Parallel | N=30 Mild/mod | | Open comedones (count) Baseline counts: 22 (Target)/40 (Comparator) | Short (6) | Percent Change*: −62 | NS | Percent Change*: −68 | NS | NS
336 ↑ Parallel | N=56 Mod | | Papules (count) Count location: Well defined regions. Baseline counts: 29 (Target)/19 (Comparator) | Short (6) | Percent Change*: −39 | NS | Percent Change*: 05 | NS | NS*
259 ↓ Parallel | N=30 Mild/mod | | Papules (count) Baseline counts: 14 (Target)/16 (Comparator) | Short (6) | Percent Change*: −25 | NS | Percent Change*: −48 | NS | NS
| | | Pustules (count) Baseline counts: 4 (Target)/2 (Comparator) | Short (6) | Percent Change*: −33 | NS | Percent Change*: 87 | NS | NS
336 ↑ Parallel | N=56 Mod | | Pustules (count) Count location: Well defined regions. Baseline counts: 5 (Target)/4 (Comparator) | Short (6) | Percent Change*: −43 | NS | Percent Change*: −22 | NS | NS*
259 ↓ Parallel | N=30 Mild/mod | | Closed comedones (count) Baseline counts: 19 (Target)/39 (Comparator) | Mid (12) | Percent Change*: −34 | NS | Percent Change*: −45 | NS | NS
342 ↑ Parallel | N=39 Mod | | Infiltrates (count) Baseline counts: 6 (Target)/3 (Comparator) | Mid (12) | Percent Change*: −18 | NS | Percent Change*: −27 | NS | NS
259 ↓ Parallel | N=30 Mild/mod | | Open comedones (count) Baseline counts: 22 (Target)/40 (Comparator) | Mid (12) | Percent Change*: −64 | NS | Percent Change*: −52 | NS | NS
| | | Papules (count) Baseline counts: 14 (Target)/16 (Comparator) | Mid (12) | Percent Change*: −63 | NS | Percent Change*: −63 | NS | NS
342 ↑ Parallel | N=39 Mod | | Papules (count) Baseline counts: 28 (Target)/41 (Comparator) | Mid (12) | Percent Change*: −54 | .01 | Percent Change*: −47 | .05 | NS
259 ↓Parallel | N=30 Mild/mod | | Pustules (count) Baseline counts: 4 (Target)/2 (Comparator) | Mid (12) | Percent Change*: −62 | NS | Percent Change*: −25 | NS | NS
342 ↑ Parallel | N=39 Mod | | Pustules (count) Baseline counts: 10 (Target)/7 (Comparator) | Mid (12) | Percent Change*: −05 | NS | Percent Change*: −52 | .05 | NS
133 ↑ Parallel | N=59 Mod | N.07.02 | Comedones change (count) Count location: Above jawline. Baseline counts: 39 (Target)/41 (Comparator) | Short (6) | Zinc sulfur Percent change*: −36 | .001 | Placebo Percent change*: −40 | .01 | NS
| | | Papules change (count) Count location: Above jawline. Baseline counts: 13 (Target)/12 (Comparator) | Short (6) | Percent change*: −40 | .001 | Percent change*: −23 | .01 | NS
| | | Pustules change (count) | Short (6) | Percent change*: −24 | .05 | Percent change*: 03 | NS | NS
| | | Severity change (% michaelsson) | Short (6) | Measure: −33 (26.) | .001 | Measure: −18 (33.) | .01 | 0.01
| | | Severity change (michaelsson) | Short (6) | Measure: −19 (17.7) | .001 | Measure: −11 (12.3) | .01 | 0.01
232 ↑ Parallel | N=40 Mod/sev | N.07.03 | Comedones change (count) | Mid (12) | Zinc sulfate Change: −25 (25.7) | | Oxytetracycline Change: −44 (52.6) | | NS
232 ↑ Parallel | N=40 Mod/sev | | Comedones severity change (michaelsson difference) | Mid (12) | Measure: −14 (13.9) | | Measure: −24 (29.6) | | NS
| | | Overall change/patient | Mid (12) | Measure: 2 | | Measure: 2
| | | Overall change/physician | Mid (12) | Measure: 2 | | Measure: 2
| | | Papules change (count) | Mid (12) | Change: −17 (16.9) | | Change: −11 (14.) | | NS
| | | Papules severity change (michaelsson difference) | Mid (12) | Measure: −20 (18.7) | | Measure: −14 (15.2) | | NS
| | | Pustules change (count) | Mid (12) | Change: −6 (5.6) | | Change: −3 (4.3) | | NS
| | | Pustules severity change (michaelsson difference) | Mid (12) | Measure: −13 (14.3) | | Measure: −8 (10.1) | | NS
| | | Total severity change/photo (michaelsson) | Mid (12) | Measure: 1 | | Measure: 1 | | NS
74 ↓ Parallel | N=48 Mod | N.07.03 | Nodules (count) Baseline counts: 2 (Target)/3 (Comparator) | Short (4) | Zinc sulfate/citrate complex Percent Change*: −29 | NS | Tetracycline Percent Change*: 35 | NS | NS*
| | | Non-inflammatory (count) Baseline counts: 45 (Target)/80 (Comparator) | Short (4) | Percent Change*: −02 | NS | Percent Change*: −08 | NS | NS*
| | | Overall change/patient (vas) | Short (4) | Measure: 14 (5.) | NS | Measure: 10 (6.) | NS | NS*
| | | Papules (count) Baseline counts: 30 (Target)/41 (Comparator) | Short (4) | Percent Change*: 03 | NS | Percent Change*: −29 | NS | NS*
| | | Pustules (count) Baseline counts: 12 (Target)/13 (Comparator) | Short (4) | Percent Change*: −25 | NS | Percent Change*: −38 | NS | NS*
| | | Severity (burton) | Short (4) | Measure: 3 (0.2) | NS | Measure: 3 (0.2) | NS | NS*
| | | Nodules (count) Baseline counts: 2 (Target)/3 (Comparator) | Mid (12) | Percent Change*: −13 | NS | Percent Change*: −50 | NS | NS*
| | | Non-inflammatory (count) Baseline counts: 45 (Target)/80 (Comparator) | Mid (12) | Percent Change*: −11 | NS | Percent Change*: −40 | .01 | NS*
| | | Overall change/patient (vas) | Mid (12) | Measure: 15 (4.) | NS | Measure: 28 (5.) | .01 | NS*
74 ↓ Parallel | N=48 Mod | | Papules (count) Baseline counts: 30 (Target)/41 (Comparator) | Mid (12) | Percent Change*: −13 | NS | Percent Change*: −49 | .01 | NS*
| | | Pustules (count) Baseline counts: 12 (Target)/13 (Comparator) | Mid (12) | Percent Change*: −33 | .05 | Percent Change*: −46 | .01 | NS*
| | | Severity (burton) | Mid (12) | Measure: 3 (0.1) | NS | Measure: 2 (0.1) | .01 | .001*
301 ↓ Parallel | N=73 Mod | N.08.01 | Comedones (count) Count location: Face. Baseline counts: 33 (Target)/29 (Comparator) | Short (6) | Erythromycin + zinc Percent Change*: −61 | | Vehicle Percent Change*: −38 | | 0.05
| | | Inflammatory (count) Count location: Face. Baseline counts: 20 (Target)/28 (Comparator) | Short (6) | Percent Change*: −65 | | Percent Change*: −25 | | 0.01
| | | Severity (cook) Count location: Face. | Short (6) | Measure: 3 | .05 | Measure: 5 | | 0.05
| | | Severity change (cook) | Short (6) | Measure: −2 | | Measure: −1
| | | Severity (cook) | Mid (10) | Measure: 2 | | Measure: 5 | | 0.05
| | | Comedones (count) Count location: Face. Baseline counts: 33 (Target)/29 (Comparator) | Mid (12) | Percent Change*: −61 | | Percent Change*: −48
| | | Inflammatory (count) Count location: Face. Baseline counts: 20 (Target)/28 (Comparator) | Mid (12) | Percent Change*: −73 | | Percent Change*: −46 | | 0.01
| | | Severity change (cook) Count location: Face. | Mid (12) | Measure: −3 | | Measure: −1 | | 0.001
321 Parallel | N=22 Mild/mod | N.08.01 | Inflammatory change (%) Count location: Entire face. | Short (4) | Zinc + erythromycin Percent change: −55 (16.) | | Vehicle Percent change: −29 (16.) | | NS
| | | Inflammatory change (%) | Mid (10) | Percent change: −60 (38.) | | Percent change: −12 (63.) | | 0.05
147 ↑ Parallel | N=122 Mod | N.08.02 | Comedones change (%) | Short (4) | Erythromycin + zinc Percent change: −35 | | Erythromycin Percent change: −25 | | NS
| | | Inflammatory change (%) Count location: Face. | Short (4) | Percent change: −62 | | Percent change: −42 | | 0.001
| | | Severity (cook) | Short (4) | Measure: 3 | | Measure: 3 | | NS
| | | Comedones change (%) | Mid (12) | Percent change: −62 | | Percent change: −40 | | 0.001
| | | Inflammatory change (%) | Mid (12) | Percent change: −85 | | Percent change: −48 | | 0.001
| | | Macules (count) Count location: Face. Baseline counts: 9 (Target)/9 (Comparator) | Mid (12) | Percent Change*: −36 | .01 | Percent Change*: 00 | .02
| | | Nodules (count) Count location: Face. Baseline counts: 1 (Target)/1 (Comparator) | Mid (12) | Percent Change*: −100 | .01 | Percent Change*: −60 | NS
| | | Severity (cook) Count location: Face. | Mid (12) | Measure: 2 | | Measure: 3 | | 0.001
28 ↑ Parallel | N=45 Mild/mod | N.08.02 | Inflammatory (count) Baseline counts: 57 (Target)/54 (Comparator) | Short (4) | Erythromycin + zinc acetate Percent Change*: −25 | .001 | Erythromycin Percent Change*: −35 | .01 | NS*
| | | Non-inflammatory (count) Baseline counts: 55 (Target)/52 (Comparator) | Short (4) | Percent Change*: −27 | .01 | Percent Change*: −23 | .01 | NS*
| | | Severity (leeds) | Short (4) | Measure: 1 (0.5) | .001 | Measure: 0 (0.5) | .001 | NS*
| | | Inflammatory (count) Baseline counts: 57 (Target)/54 (Comparator) | Mid (12) | Percent Change*: −51 | .001 | Percent Change*: −57 | .001 | NS*
| | | Non-inflammatory (count) Baseline counts: 55 (Target)/52 (Comparator) | Mid (12) | Percent Change*: −55 | .001 | Percent Change*: −44 | .001 | NS*
| | | Severity (leeds) | Mid (12) | Measure: 0 (0.4) | .001 | Measure: 0 (0.5) | .001 | NS*
300 Parallel | N=103 Mod | N.08.03 | Comedones change (%) Count location: Face. | Short (6) | Erythromycin + zinc Percent change: −65 | sig | Clindamycin phosphate Percent change: −55 | sig | 0.01
| | | Severity change (cook %) | Short (6) | Measure: −50 | sig | Measure: −30 | sig | 0.001
| | | Total inflammatory change (%) | Short (6) | Percent change: −60 | sig | Percent change: −40 | sig | 0.05
| | | Comedones change (%) | Mid (12) | Percent change: −75 | sig | Percent change: −65 | sig | NS
| | | Severity change (cook %) | Mid (12) | Measure: −60 | sig | Measure: −50 | sig | NS
| | | Total inflammatory change (%) | Mid (12) | Percent change: −65 | sig | Percent change: −55 | sig | 0.05

TRIAL:↑↓ -presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., - our assessment of entry severity of study patients. “P”- parallel study, “S”- split face design. TARGET and COMPARATOR: “Percent change”- an outcome derived from individual final and baseline measures; “Percent change*”- we calculated a group-based percentage change; “Change” - raw difference from baseline; “Change*” - calculated change; “Measure” - an outcome measure with no baseline comparison. SD: standard deviation. WITHIN P: P-value with respect to baseline in one arm. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table N3: DISCRETE outcomes for class OTHER

Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Treatment | Comparator | Between P-value
Trial # Method Info | Comparison | Discrete Outcome Name (Units) Definition/Comments | Follow-up (wks) | Attribute: Number of patients | Attribute: Number of patients | Between P-value
325 ↑ Parallel Sev N=20 | N.01.02 | Severity change (michaelsson) | Mid (12) | Gugulipid Excellent 3 Good 7 Poor 0 | Tetracycline Excellent 2 Good 6 Poor 2 | 0.05
| | Post-therapy relapse | Long (96) | Relapse 2 No relapse 8 | Relapse 4 No relapse 6
94 Parallel Mild/mod N=70 | N.01.03 | Burning | Mid (12) | Isolutrol Present 1 Absent 34 | Benzoyl peroxide Present 12 Absent 23 | 0.05
| | Dryness | Mid (12) | Present 11 Absent 24 | Present 29 Absent 6 | 0.05
| | Erythema | Mid (12) | Present 3 Absent 32 | Present 17 Absent 18 | 0.05
| | Pruritis | Mid (12) | Present 5 Absent 30 | Present 15 Absent 20 | 0.05
| | Scaling | Mid (12) | Present 3 Absent 32 | Present 25 Absent 10 | 0.005
17 ↓ Parallel N=51 | N.01.04 | Severity change (grade) | Mid (8) | Ocimum basilicum 100% reduction 0 >50% reduction 20 <50% reduction 3 No reduction 0 | Tetracycline 100% reduction 0 >50% reduction 14 <50% reduction 3 No reduction 6
| | | | Increase 2 | Increase 3
18 ↑ Parallel Mod N=124 | N.01.05 | Unwanted effects | Mid (12) | Tea tree oil Present 27 Absent 31 | Benzoyl peroxide Present 50 Absent 13 | 0.001
| N.02.01 | | | Clobetasol | Vehicle
175 ↑ Parallel split face Mod N=11 | | Severity change | Short (3) | Overall reduction in active lesions 6 Overall increase in active lesions 2 Little change 3 | Overall reduction in active lesions 1 Overall increase in active lesions 0 Little change 10 | NS
228 Parallel N=776 | N.02.04 | Overall change/physician | Short (5) | Neomycin + methyl prednisolone Improved 355 Not improved 69 | Vehicle Improved 76 Not improved 75 | 0.001
102 ↑ Parallel N=134 | N.02.05 | Overall change | | Methyl prednisolone + neomycin + sulfur Excellent 29 Good 22 Same 13 Worse 2 | Vehicle Excellent 16 Good 20 Same 27 Worse 5 | 0.02
228 Parallel N=776 | N.02.06 | Overall change/physician | Short (5) | Neomycin + methyl prednisolone Improved 355 Not improved 69 | Aluminum chlorhydroxide + sulfur Improved 142 Not improved 59 | 0.001
189 Parallel Mod/sev N=40 | N.03.01 | Overall change/physician | Long (80) | Gamma-globulin None 5 Fair 4 Good 7 Very good 8 | Placebo None 1 Fair 3 Good 8 Very good 4
| | Side effects | Long (80) | Pain 2 | Pain 0
222 ↑ Parallel Mild/mod/sev N=66 | N.03.03 | Adverse reation | Short (1) | Staphylococcal toxoid Colds with fever 10 Axillary adenitis 2 | Vehicle Colds with fever 2 Axillary adenitis 0
222 ↑ Parallel Mild/mod/sev N=66 | | Overall change/patient | Mid (10) | Cure complete 0 Great improvement 5 Partial improvement 16 No improvement 12 | Cure complete 0 Great improvement 0 Partial improvement 5 No improvement 25
| | Overall change/physician [mild] | Mid (10) | Worse 1 Improved 9 Not improved 5 | Worse 2 Improved 3 Not improved 4
| | Overall change/physician [moderate] | Mid (10) | Improved 9 Not improved 6 | Improved 10 Not improved 12
| | Overall change/physician [severe] | Mid (10) | Improved 5 Not improved 0 | Improved 2 Not improved 1
| | Overall change/patient | Long (24) | Cure complete 0 Great improvement 8 Partial improvement 15 No improvement 11 | Cure complete 0 Great improvement 2 Partial improvement 13 No improvement 16
| | Overall change/physician [mild] | Long (24) | Worse 0 Improved 7 No 7 | Worse 1 Improved 1 No 6
| | Overall change/physician [moderate] | Long (24) | Improved 11 Not improvement 4 | Improvement 4 Not improvement 18
| | Overall change/physician [severe] | Long (24) | Improved 3 Not improved 2 | Improved 0 Not improved 3
297 Parallel Mild/mod N=32 | N.04.01 | Overall change/patient | Short (4) | Chloramphenicol + hydrocortisone Definitely better 12 Possibly better 2 No change 0 Worse 0 | Vehicle Definitely better 6 Possibly better 5 No change 3 Worse 0 | 0.05
| | Overall change/physician | Short (4) | Missing 1 Definitely better 12 Possibly better 1 No change 1 Worse 0 | Missing 1 Definitely better 6 Possibly better 4 No change 4 Worse 0
| | | | Missing 1 | Missing 1
297 Parallel Mild/mod N=32 | | Severity (burton) | Short (4) | 0 0 1 8 2 5 3 1 | 0 0 1 1 2 12 3 1 | 0.05
| | Overall change/patient | Mid (8) | No record 1 Definitely better 10 Possibly better 2 No change 1 Worse 0 | No record 1 Definitely better 4 Possibly better 1 No change 7 Worse 2 | 0.05
| | Overall change/physician | Mid (8) | Missing 2 Definitely better 10 Possibly better 2 No change 1 Worse 0 | Missing 1 Definitely better 4 Possibly better 2 No change 5 Worse 3
| | Severity (burton) | Mid (8) | Missing 2 0 0 1 12 2 1 3 0 | Missing 1 0 0 1 6 2 4 3 4
| | Withdrawals due to side effects | Mid (8) | No record 2 Withdraw 0 Did not withdraw 15 | No record 1 Withdraw 5 Did not withdraw 10 | 0.014
224 ↑ Cross-over Mild/mod/sev N=120 | N.04.02 | Side effects | Mid (10) | Hydrocortisone + buttoxethyl nicotinate + chloramp Itchiness/ dryness 5 | Vehicle Itchiness/ dryness 3
142 Parallel Mild/mod N=50 | N.04.03 | Overall change/patient | Short (4) | Chloramphenicol + hydrocortisone + sulfur Improved 22 Not improved or worse 0 | Chloramphenicol + sulfur Improved 21 Not improved or worse 1 | NS
142 Parallel Mild/mod N=50 | | Overall change/physician | Short (4) | Improved 22 Not improved or worse 0 | Improved 22 Not improved or worse 0 | NS
| | Overall change/patient | Mid (12) | Improved 13 Not improved or worse 9 | Improved 14 Not improved or worse 8 | NS
| | Overall change/physician | Mid (12) | Improved 11 Not improved or worse 11 | Improved 15 Not improved or worse 7 | NS
115 ↑ Parallel N=37 | N.04.04 | Overall change/patient | Short (4) | Chloramphenicol + hydrocortisone + sulfur Improved 14 Same 2 Worse 0 No data 0 | Hydrocortisone + sulfur Improved 12 Same 8 Worse 1 No data 0
| | Overall change/physician | Short (4) | Improved 14 Same 2 Worse 0 No data 0 | Improved 15 Same 5 Worse 1 No data 0
| | Local reactions | Mid (12) | Irritant and poor cosmesis 0 | Irritant and poor cosmesis 1
| | Overall change/patient | Mid (12) | Improved 8 Same 3 Worse 2 No data 3 | Improved 7 Same 6 Worse 3 No data 5
| | Overall change/physician | Mid (12) | Improved 9 Same 2 Worse 2 No data 3 | Improved 7 Same 6 Worse 4 No data 4
75 ↑ Parallel Mod N=48 | N.04.05 | Erythema | Mid (12) | Chloramphenicol + hydrocortisone + sulfur Necessitating treatment reduction 5 | Benzoyl peroxide Necessitating treatment reduction 2
| | Scaling | Mid (12) | Necessitating treatment reduction 4 | Necessitating treatment reduction 6
138 ↑ Parallel split face N=40 | N.05.01 | Post-therapy overall state/observer | Mid (7) | Grenz rays Better 10 Same 19 Worse 4 | Sham rays Better 4 Same 19 Worse 10
| | Post-therapy overall state/observer | Mid (9) | Better 14 Same 14 Side 1 | Better 1 Same 14 Side 14
139 ↑ Parallel split face N=33 | | Post-therapy overall state/observer | Mid (7) | Better 9 Same 12 Worse 2 | Better 2 Same 12 Worse 9
| | Post-therapy overall state/observer | Mid (9) | Better 12 Same 14 Worse 2 | Better 2 Same 14 Worse 12
| | Post-therapy overall state/observer | Long (16) | Better 1 Same 8 Worse 1 | Better 1 Same 8 Worse 1
179 Parallel split face N=40 | | Improvement | Short (5) | Worse 1 Unchanged 15 Improved 10 Greatly improved 12 | Worse 2 Unchanged 16 Improved 12 Greatly improved 8
180 Parallel split face N=42 | | Severity change (group %) | Short (4) | Worse 3 Unchanged 9 Improved 16 Greatly improved 18 | Worse 3 Unchanged 13 Improved 18 Greatly improved 8
216 ↑ Parallel split face N=12 | N.05.02 | Inflammatory change | Long (24) | Comedone extraction (cheeks/forehead) Better 8 Worse 4 | Untreated Better 4 Worse 8
| N.06.04 | | | Hydrochlorthiazide | Placebo
284 ↓ Parallel N=50 | | Overall change | Mid (8) | Usual 12 Less 4 Better 9 | Usual 18 Less 0 Better 7
178 ↓ Cross-over N=42 | N.06.04 | Premenstrual overall change/patient [phase ii] | Short (4) | Hydrochlorthiazide Poor 11 Fair 3 Good 6 Excellent 1 | Vehicle Poor 6 Fair 4 Good 7 Excellent 4
| | Premenstrual overall change/physician [phase i] | Short (4) | Reduced 7 Not reduced 14 | Reduced 12 Not reduced 9
| | Adverse reactions/No withdrawals | Mid (8) | Headache 20 Unresolved edema 3 | Headache 15 Unresolved edema 6
| | Adverse reactions/Withdrawals | Mid (8) | Itching 1 Dizziness and heartburn 1 Nausea 1 Weakness 1 | Itching 0 Dizziness and heartburn 0 Nausea 0 Weakness 0
| | Premenstrual change/patient [phase ii] | Mid (8) | Fainting/lethargy 0 Poor 5 Fair 10 Good 5 Excellent 1 | Fainting/lethargy 1 Poor 10 Fair 5 Good 5 Excellent 3
| | Premenstrual overall change/physician [phase ii] | Mid (8) | Reduced 8 Not reduced 13 | Reduced 8 Not reduced 13
110 ↑ Parallel Mod/sev N=30 | N.06.05 | Overall change/patient | Mid (12) | Tolbutamide Worse 0 Same 5 Improved 8 | Vehicle Worse 1 Same 6 Improved 10
| | Overall change/physician | Mid (12) | Worse 0 Same 6 Improved 7 | Worse 0 Same 7 Improved 10
| | Severity/photo | Mid (12) | Worse 2 Same 6 Improved 5 | Worse 2 Same 6 Improved 9
91 ↑ Parallel Mod N=66 | N.07.02 | Nausea | | Zinc Nausea 3 | Placebo Nausea 3
| | Severity/patient | Mid (8) | Improvement-none 12 Improvement-slight 11 Improvement-marked 9 | Improvement-none 22 Improvement-slight 8 Improvement-marked 4 | 0.002
| | Severity/photo | Mid (8) | Improvement-none 8 Improvement-slight 12 Improvement -marked 12 | Improvement-none 26 Improvement-slight 5 Improvement-marked 3 | 0.0001
3 Parallel N=42 | N.07.02 | Overall change/physician | Mid (12) | Zinc sulfate Better 8 No change 3 Worse 6 | Placebo Better 7 No change 6 Worse 5
341 ↑ Parallel Mild/mod N=52 | | GI distress | Mid (12) | Nausea/vomiting (withdraw) 6 Nausea/vomiting (remained) 5 Diarrhea 3 | Nausea/vomiting (withdraw) 0 Nausea/vomiting (remained) 1 Diarrhea 0
336 ↑ Parallel Mod N=56 | N.07.02 | Oilness | Short (6) | Zinc sulfate No change 12 Less oiliness/seborrhea 17 | Vehicle No change 27 Less oiliness/seborrhea 0
| | Severity change | Short (6) | Excellent 3 Moderate 10 Slight 1 Very slight 11 | Excellent 12 Moderate 3 Slight 2 Very slight 10
| | Side effects | Short (6) | Aggravation 2 Nausea/withdraw 1 Nausea 3 None 25 | Aggravation 2 Nausea/withdraw 0 Nausea 0 None 27
342 ↑ Parallel Mod N=39 | | Side effects | | Nausea/ vomiting (withdraw) 2 Nausea/ vomiting (no withdraw) 3 | Nausea/ vomiting (withdraw) 0 Nausea/ vomiting (no withdraw) 0
| N.07.02 | | | Zinc suphate | Placebo
163 Parallel Mod/sev N=112 | | Withdrawal due to side effects | | Nausea & vomiting 1 Diarrhea 1 Fatigue & headache 0 Pruritis 1 | Nausea & vomiting 2 Diarrhea 1 Fatigue & headache 1 Pruritis 0 | NS
| | Overall change/patient | Short (4) | Much improved 11 Improved 14 Somewhat improved 13 Unchanged 7 | Much improved 8 Improved 5 Somewhat improved 15 Unchanged 9 | 0
| | Overall change/physician | Short (4) | Worse 1 Much worse 0 Much improved 9 Improved 17 Somewhat improved 11 Unchanged 5 | Worse 3 Much worse 0 Much improved 7 Improved 8 Somewhat improved 13 Unchanged 7 | NS
| | Overall change/patient | Mid (12) | Worse 3 Much worse 1 Much improved 23 Improved 13 Somewhat improved 7 Unchanged 4 | Worse 5 Much worse 0 Much improved 14 Improved 8 Somewhat improved 12 Unchanged 7 | 0.02
| | Overall change/physician | Mid (12) | Worse 1 Much worse 0 Much improved 20 Improved 18 Somewhat improved 2 Unchanged 6 | Worse 2 Much worse 0 Much improved 13 Improved 10 Somewhat improved 8 Unchanged 8 | 0.01
| | Side effects | Mid (12) | Worse 2 Much worse 0 Slight nausea initially 2 Vomiting 1 Gastric discomfort 1 Dryness of mouth 1 | Worse 4 Much worse 0 Slight nausea initially 0 Vomiting 0 Gastric discomfort 0 Dryness of mouth 0 | NS
| | | | Slight gastric discomfort 0 Nausea 0 | Slight gastric discomfort 1 Nausea 1
| N.08.02 | | | Erythromycin + zinc | Erythromycin
147 ↑ Parallel Mod N=122 | | Local side effects | | Withdraw 2 Mild 11 | Withdraw 2 Mild 6
300 Parallel Mod N=103 | N.08.03 | Cutaneous | | Erythromycin + zinc Burning/redness/withdraw 1 Irritation 0 Absent 47 | Clindamycin phosphate Burning/redness/withdraw 0 Irritation 1 Absent 43

TRIAL:↑↓ -presence of positive or negative methodological features (see Summary Table). “Mild/mod,” etc., - our assessment of entry severity of study patients. “P”- to parallel study, “S”- split face design. BETWEEN P-VALUE: comparison between Target and Comparator arms.

Evidence Table MULTI.1. Trials with MULTI-ARM outcomes

Trial/ Arm /Treatment | | Design, acne severity/ Dose, route, frequency
Trial # 53 Benzoyl peroxide Erythromycin Erythromycin Vehicle | n=177 | ↓ Parallel;Mod/sev 5% topical bid. 3% topical bid. 3% topical bid. no dose information.
Trial # 97 Chlorhydroxyquinoline Chlorhydroxyquinoline Hydrocortisone Benzoyl peroxide Benzoyl peroxide Benzoyl peroxide Vehicle | n=196 | ↑ Parallel;Mild/mod 0.25% topical (1 to 4 times daily) 0.25% topical (1 to 4 times daily) 0.5% topical (1 to 4 times daily) 5.5% topical (1 to 4 times daily) 5.5% topical (1 to 4 times daily) 5.5% topical (1 to 4 times daily) no dose information.
Trial # 108 Erythromycin Placebo (oral) Placebo (oral) Zinc (gel) Erythromycin Zinc acetate Placebo (oral) Placebo (topical) Tretracycline (oral) Placebo (topical) | n=149 | Parallel;Mild/mod/sev 4% topical bid. no dose information. no dose information. 1.2% topical bid. 4% topical bid. 1.2% topical bid. no dose information. no dose information. 250mg oral bid. no dose information.
Trial # 109 Benzoyl peroxide Benzoyl peroxide Benzoyl peroxide Untreated | n=42 | ↓ Parallel;Mod no dose information. no dose information. no dose information. no dose information.
Trial # 119 Adapalene Petrolatum Tretinoin Tretinoin Tretinoin Tretinoin Tretinoin | n=28 | ↑ Parallel;Split face; 0.1% topical qd. no dose information. 0.025% topical qd. 0.01% topical qd. 0.05% topical qd. 0.1% topical qd. 0.025% topical qd.
Trial # 120 Adapalene Petrolatum Tretinoin Tretinoin Tretinoin Tretinoin | n=27 | ↑ Parallel;Split face; 0.1% topical qd. no dose information. 0.025% topical qd. 0.1% topical qd. 0.1% topical qd. 0.1% topical qd.
Trial # 132 Placebo Spironolactone Spironolactone Spironolactone Spironolactone | n=36 | ↑ Parallel;Sev no dose information. 100mg oral (can't say) 150mg oral (can't say) 50mg oral (can't say) 200mg oral (can't say)
Trial # 149 Benzoyl peroxide Benzoyl peroxide Tretinoin benzoyl peroxide Tretinoin Benzoyl peroxide Tretinoin | n=250 | ↓ Parallel;Mild/mod/sev 10% topical bid. 5% topical bid. 0.05% topical qhs. 5% topical qhs. 0.05% topical qhs. 10% topical qhs. 0.05% topical bid.
Trial # 156 Cimetidine Cimetidine Spironolactone Spironolactone | n=50 | ↓ Parallel;Mod/sev 1.6g oral (*) 1.6g oral (*) 100mg oral qd. 100mg oral qd.
Trial # 177 Benzoyl peroxide Hydrocortisone Benzoyl peroxide Potassium hydroxyquinol Benzoyl peroxide Potassium hydroxyquinol Vehicle | n=107 | ↑ Parallel; 10% topical bid. 1% topical bid. 10% topical bid. 0.5% topical bid. 10% topical bid. 0.5% topical bid. no dose information.
Trial # 214 Benzoyl peroxide Benzoyl peroxide Clindamycin Clindamycin Vehicle | n=393 | ↓ Parallel;Mod 5% topical qhs. 5% topical qhs. 1% topical qhs. 1% topical qhs. no dose information.
Trial # 229 Clindamycin hydrochlori Clindamycin phosphate Clindamycin phosphate Clindamycin hydrochlori E-solve Ionax | n=88 | ↓ Parallel;Split face;Mod/sev 2% topical bid. 2% topical bid. 2% topical bid. 2% topical bid. no dose information. no dose information.
Trial # 233 Vehicle Vitamin A palmitate Zinc sulfate Zinc sulfate Vitamin A palmitate | n=64 | ↓ Parallel;Mod/sev no dose information. 15000IU oral bid. 0.2g oral tid. 0.2g oral tid. 15000IU oral bid.
Trial # 238 Erythromycin Tretinoin Erythromycin base Tretinoin Vehicle | n=80 | ↓ Parallel;Mod/sev 2% topical bid. 0.05% topical qhs. 2% topical bid. 0.05% topical qhs. no dose information.
Trial # 239 Aluminum Oxide Sulfur Polyester Polyethylene Polystyrene Pumice | n=50 | ↓ Parallel;Mod/sev no dose information. no dose information. no dose information. no dose information. no dose information. no dose information.
Trial # 266 Placebo Shankhabhasma vah Sookshama triphala Sunder vati Thiostanin | n=82 | ↓ Parallel;Mod 500mg oral tid. 500mg oral tid. 500mg oral tid. 500mg oral tid. 500mg oral tid.
Trial # 287 Hydrocortisone Neomycin Resorcinol Sulphur Hydrocortisone F Resorcinol Neomycin Sulphur Vehicle | n=79 | ↓ Parallel; 0.5% topical bid. 0.5% topical bid. 1.5% topical bid. 2.7% topical bid. 0.5% topical bid. 1.5% topical bid. 0.5% topical bid. 2.7% topical bid. no dose information.
Trial # 288 Hydrocortisone Hydrocortisone Sulphur Neomycin Sulphur Sulphur Hydrocortisone Resorcinol Neomycin Neomycin Resorcinol Sulphur Vehicle | n=188 | ↓ Parallel; 1% topical bid. 1 topical bid. 4% topical bid. 0.5% topical bid. 4% topical bid. 4% topical bid. 1% topical bid. 2% topical bid. 0.5% topical bid. 0.5% topical bid. 2% topical bid. 4% topical bid. no dose information.
Trial # 302 Tretinoin Tretinoin Tretinoin Tretinoin | n=20 | ↓ Parallel;Split face;Mi 0.05% topical qhs. 0.01% topical qhs. 0.025% topical qhs. 0.025% topical qhs.
Trial # 340 Erythromycin proprionate Erythromycin stearate Placebo Tetracycline-novobiocin Tetracycline phosphate Tetracycline-citric acid Triacetyl-oleandomycin | n=91 | ↓ Parallel;Mod/sev no dose information. no dose information. no dose information. no dose information. no dose information. no dose information. no dose information.
Trial # 349 Ibuprofen Placebo Tetracycline hydrochlorid Ibuprofen Placebo (ibuprofen) Placebo Placebo Tetracycline hydrochlorid | n=68 | ↓ Parallel;Mild/mod 600mg oral qid. no dose information. 250mg oral qid. 600mg oral qid. no dose information. no dose information. no dose information. 250mg oral qid.
Trial # 350 Grenz rays Hexachlorophene Grenz rays Hexachlorophene Placebo Untreated | n=95 | ↓ Parallel;Split face;Sev 200rads other (monthly) no dose information. 200rads other (monthly) no dose information. no dose information. no dose information.

Evidence Table MULTI.2. Continuous outcomes of MULTI-ARM trials

Trial | Continuous Outcome Name (Units) Comments re Between P-value | Follow up | Treatment | | | Between P-value
Trial | Continuous Outcome Name (Units) Comments re Between P-value | Follow up | Data Type: Mean (SD) | SS | Within P | Between P-value
53 ↓ P Mod/sev | Comedones change (%) | Short (6) | Benzoyl peroxide Percent change: −28 | 44 | | NS
53 ↓ P Mod/sev | Comedones change (%) Vs Placebo | Mid (10) | Benzoyl peroxide Percent change: −28 | 44 | | “Sig”
53 ↓ P Mod/sev | Comedones change (%) | Short (6) | Erythromycin Percent change: −12 | 45 | | NS
53 ↓ P Mod/sev | Comedones change (%) Vs Placebo | Mid (10) | Erythromycin Percent change: −18 | 45 | | “Sig”
53 ↓ P Mod/sev | Comedones change (%) | Short (6) | Erythromycin + benzoyl peroxide Percent change: −28 | 44 | | NS
53 ↓ P Mod/sev | Comedones change (%) Vs Placebo | Mid (10) | Erythromycin + benzoyl peroxide Percent change: −28 | 44 | | “Sig”
53 ↓ P Mod/sev | Comedones change (%) | Short (6) | Vehicle Percent change: −12 | 44 | | NS
53 ↓ P Mod/sev | Comedones change (%) | Mid (10) | Vehicle Percent change: −2 | 44 | | NS
53 ↓ P Mod/sev | Inflammatory change (%) Vs Placebo; BP = E | Short (6) | Benzoyl peroxide Percent change: −42 | 44 | | “Sig”
53 ↓ P Mod/sev | Inflammatory change (%) Vs Placebo; BP = E | Mid (10) | Benzoyl peroxide Percent change: −58 | 44 | | “Sig”
53 ↓ P Mod/sev | Inflammatory change (%) Vs Placebo; E = BP | Short (6) | Erythromycin Percent change: −42 | 45 | | “Sig”
53 ↓ P Mod/sev | Inflammatory change (%) Vs Placebo; E = BP | Mid (10) | Erythromycin Percent change: −60 | 45 | | “Sig”
53 ↓ P Mod/sev | Inflammatory change (%) Vs BP, E, Placebo | Short (6) | Erythromycin + benzoyl peroxide Percent change: −62 | 44 | | “Sig”
53 ↓ P Mod/sev | Inflammatory change (%) Vs BP, E, Placebo | Mid (10) | Erythromycin + benzoyl peroxide Percent change: −78 | 44 | | “Sig”
53 ↓ P Mod/sev | Inflammatory change (%) | Short (6) | Vehicle Percent change: −15 | 44 | | NS
53 ↓ P Mod/sev | Inflammatory change (%) | Mid (10) | Vehicle Percent change: −28 | 44 | | NS
53 ↓ P Mod/sev | Papules change (%) Vs Placebo; BP = E | Short (6) | Benzoyl peroxide Percent change: −38 | 44 | | “Sig”
53 ↓ P Mod/sev | Papules change (%) Vs Placebo; BP = E | Mid (10) | Benzoyl peroxide Percent change: −54 | 44 | | “Sig”
53 ↓ P Mod/sev | Papules change (%) Vs Placebo; E = BP | Short (6) | Erythromycin Percent change: −40 | 45 | | “Sig”
53 ↓ P Mod/sev | Papules change (%) Vs Placebo; E = BP | Mid (10) | Erythromycin Percent change: −50 | 45 | | “Sig”
53 ↓ P Mod/sev | Papules change (%) Vs E | Short (6) | Erythromycin + benzoyl peroxide Percent change: −58 | 44 | | “Sig”
53 ↓ P Mod/sev | Papules change (%) Vs E | Mid (10) | Erythromycin + benzoyl peroxide Percent change: −70 | 44 | | “Sig”
53 ↓ P Mod/sev | Papules change (%) | Short (6) | Vehicle Percent change: −15 | 44 | | NS
53 ↓ P Mod/sev | Papules change (%) | Mid (10) | Vehicle Percent change: −30 | 44 | | NS
53 ↓ P Mod/sev | Pustules change (%) Vs Placebo; BP = E = E + BP | Short (6) | Benzoyl peroxide Percent change: −55 | 44 | | “Sig”
53 ↓ P Mod/sev | Pustules change (%) Vs Placebo | Mid (10) | Benzoyl peroxide Percent change: −70 | 44 | | “Sig”
53 ↓ P Mod/sev | Pustules change (%) Vs Placebo; E = BP = E + BP | Short (6) | Erythromycin Percent change: −48 | 45 | | “Sig”
53 ↓ P Mod/sev | Pustules change (%) Vs Placebo | Mid (10) | Erythromycin Percent change: −70 | 45 | | “Sig”
53 ↓ P Mod/sev | Pustules change (%) Vs Placebo; E + BP = BP = E | Short (6) | Erythromycin + Benzoyl peroxide Percent change: −80 | 44 | | “Sig”
53 ↓ P Mod/sev | Pustules change (%) Vs Placebo | Mid (10) | Erythromycin + Benzoyl peroxide Percent change: −90 | 44 | | “Sig”
53 ↓ P Mod/sev | Pustules change (%) | Short (6) | Vehicle Percent change: −10 | 44 | | NS
53 ↓ P Mod/sev | Pustules change (%) | Mid (10) | Vehicle Percent change: −28 | 44 | | NS
97 ↑ P Mild/mod | Total lesions change (%) With respect to placebo | Short (4) | Benzoyl peroxide Percent change: −37 | 48 | M | 0.001
97 ↑ P Mild/mod | Total lesions change (%) With respect to placebo | Short (4) | Benzoyl peroxide + chlorhydroxyquinoline Percent change: −56 | 54 | M | NS
97 ↑ P Mild/mod | Total lesions change (%) With respect to placebo | Short (4) | Vehicle Percent change: 6 | 48 | M | 0.001
108 P Mild/mod/se v | Medication used (mg/kg) | Mid (10) | Erythromycin + zinc (gel) + Placebo (oral) Raw measure: 27 | 39
108 P Mild/mod/se v | Medication used (mg/kg) | Mid (10) | Erythromycin + zinc (gel) + Placebo (oral) Raw measure: 86 | 40
108 P Mild/mod/se v | Medication used (mg/kg) | Mid (10) | Tetracycline (oral) + placebo (topical) Raw measure: 463 | 39
108 P Mild/mod/se v | Papules change (%) Gel = tet liq > pl | Short (6) | Erythromycin + zinc (gel) + Placebo (oral) Percent change: −39 (50.) | 39 | | 0.05
108 P Mild/mod/se v | Papules change (%) EZ liquid, gel = Tet | Mid (10) | Erythromycin + zinc (gel) + Placebo (oral) Percent change: −45 (50.) | 39 | | 0.05
108 P Mild/mod/se v | Papules change (%) Gel = tet liq > pl | Short (6) | Erythromycin + zinc (gel) + Placebo (oral) Percent change: −52 (50.) | 40 | | 0.001
108 P Mild/mod/se v | Papules change (%) EZ liquid, gel = Tet | Mid (10) | Erythromycin + zinc (gel) + Placebo (oral) Percent change: −58 (50.) | 40 | | 0.001
108 P Mild/mod/se v | Papules change (%) Gel = tet liq > pl | Short (6) | Placebo (topical) + placebo (oral) Percent change: −23 (50.) | 31
108 P Mild/mod/se v | Papules change (%) EZ liquid, gel = Tet | Mid (10) | Placebo (topical) + placebo (oral) Percent change: −25 (50.) | 31 | | NS
108 P Mild/mod/se v | Papules change (%) Gel = tet liq > pl | Short (6) | Tetracycline (oral) + placebo (topical) Percent change: −55 (50.) | 39
108 P Mild/mod/se v | Papules change (%) EZ liquid, gel = Tet | Mid (10) | Tetracycline (oral) + placebo (topical) Percent change: −51 (50.) | 39 | | 0.01
108 P Mild/mod/se v | Severity change (Cook) | Short (6) | Erythromycin + zinc (gel) + Placebo (oral) Raw measure: −33 (50.) | 39 | | 0.01
108 P Mild/mod/se v | Severity change (Cook) | Short (6) | Erythromycin + zinc (gel) + Placebo (oral) Raw measure: −39 (50.) | 40 | | 0.001
108 P Mild/mod/se v | Severity change (Cook) | Short (6) | Placebo (topical) + placebo (oral) Raw measure: 14 (50.) | 31 | | NS
108 P Mild/mod/se v | Severity change (Cook) | Short (6) | Tetracycline (oral) + placebo (topical) Raw measure: −35 (50.) | 39 | | 0.01
108 P Mild/mod/se v | Severity change (Cook) | Mid (10) | Erythromycin + zinc (gel) + Placebo (oral) Raw measure: −33 (50.) | 39 | | 0.01
108 P Mild/mod/se v | Severity change (Cook) | Mid (10) | Erythromycin + zinc (gel) + Placebo (oral) Raw measure: −46 (50.) | 40 | | 0.001
108 P Mild/mod/se v | Severity change (Cook) | Mid (10) | Placebo (topical) + placebo (oral) Raw measure: −7 (50.) | 31
108 P Mild/mod/se v | Severity change (Cook) | Mid (10) | Tetracycline (oral) + placebo (topical) Raw measure: −32 (50.) | 39 | | 0.01
109 ↓ P Mod | Total lesions (count) | Mid (12) | Benzoyl peroxide (contingent contract) Change*: −8 | *21 | 0.0001 | 0.04
109 ↓ P Mod | Total lesions (count) | Mid (12) | Benzoyl peroxide (non-contingent contract) Change*: −13 | *21 | 0.0001 | 0.04
109 ↓ P Mod | Total lesions (count) | Mid (12) | Benzoyl peroxide (self monitoring) Change*: −15 | *21 | 0.0001 | 0.04
109 ↓ P Mod | Total lesions (count) | Mid (12) | Untreated Change*: 0 | *21 | M | NS
119 ↑ P s | Irritation (score) | Short (3) | Adapalene Raw measure: 0 | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Adapalene Raw measure: 0 (0.38) | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Petrolatum Raw measure: 0 (0.31) | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Petrolatum Raw measure: 0 | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.01% gel) Raw measure: 2 (0.37) | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.01% gel) Raw measure: 3 | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.025% cream) Raw measure: 2 | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.025% cream) Raw measure: 2 (0.37) | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.025% gel) Raw measure: 3 | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.025% gel) Raw measure: 2 (0.42) | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.05% cream) Raw measure: 2 (0.29) | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.05% cream) Raw measure: 3 | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.1% cream) Raw measure: 2 (0.34) | 28 | M | M
119 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.1% cream) Raw measure: 3 | 28 | M | M
120 ↑ P s | Irritation (score) | Short (3) | Adapalene Raw measure: 0 | 27 | M | M
120 ↑ P s | Irritation (score) | Short (3) | Petrolatum Raw measure: 0 | 27 | M | M
120 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.1% cream) Raw measure: 2 | 27 | M | M
120 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.025% cream) Raw measure: 2 | 27 | M | M
120 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.05% cream) Raw measure: 2 | 27 | M | M
120 ↑ P s | Irritation (score) | Short (3) | Tretinoin (0.1% gel) Raw measure: 2 | 27 | M | M
120 ↑ P s | Local reactions/Irritation (Cumulative score) | Short (3) | Adapalene Raw measure: 0 | 27 | M | M
120 ↑ P s | Local reactions/Irritation (Cumulative score) | Short (3) | Petrolatum Raw measure: 0 | 27 | M | M
120 ↑ P s | Local reactions/Irritation (Cumulative score) | Short (3) | Tretinoin (0.1% cream) Raw measure: 2 | 27 | M | M
120 ↑ P s | Local reactions/Irritation (Cumulative score) | Short (3) | Tretinoin (0.025% cream) Raw measure: 1 | 27 | M | M
120 ↑ P s | Local reactions/Irritation (Cumulative score) | Short (3) | Tretinoin (0.05% cream) Raw measure: 1 | 27 | M | M
120 ↑ P s | Local reactions/Irritation (Cumulative score) | Short (3) | Tretinoin (0.1% gel) Raw measure: 1 | 27 | M | M
149 ↓ P Mild/mod/se v | Time to favorable status (mean weeks) | Mid (10) | Benzoyl peroxide (5%) Raw measure: 7 | 50 | | NS
149 ↓ P Mild/mod/se v | Time to favorable status (mean weeks) | Mid (10) | Benzoyl peroxide (10%) Raw measure: 6 | 50 | | NS
149 ↓ P Mild/mod/se v | Time to favorable status (mean weeks) | Mid (10) | Tretinoin Raw measure: 7 | 50 | | NS
156 ↓ P Mod/sev | Severity (Michaelsson) | Mid (12) | Cimetidine [men] Raw measure: 60 (18.) | 9 | 0.01 | M
156 ↓ P Mod/sev | Severity (Michaelsson) | Mid (12) | Cimetidine [women] Raw measure: 44 (29.) | 16 | 0.001 | M
156 ↓ P Mod/sev | Severity (Michaelsson) | Mid (12) | Spironolactone [men] Raw measure: 48 (30.) | 10 | M | M
156 ↓ P Mod/sev | Severity (Michaelsson) | Mid (12) | Spironolactone [women] Raw measure: 32 (22.4) | 15 | M | M
177 ↑ P | Face severity (Jaffe) | Mid (12) | Benzoyl peroxide Raw measure: −3 (0.12) | 28 | 0.001 | M
177 ↑ P | Face severity (Jaffe) | Mid (12) | Hydroxyquinoline + benzoyl peroxide Raw measure: −5 (0.17) | 25 | 0.0001 | M
177 ↑ P | Face severity (Jaffe) | Mid (12) | Vehicle Raw measure: −3 (0.1) | 27 | 0.001 | M
214 ↑ P Mod | Inflammatory change (%) | Mid (11) | Benzoyl peroxide Percent change: −39 (4.) | 92 | M | 0.02
214 ↑ P Mod | Inflammatory change (%) | Mid (11) | Clindamycin Percent change: −35 (5.) | 89 | M | 0.02
214 ↑ P Mod | Inflammatory change (%) | Mid (11) | Clindamycin + benzoyl peroxide Percent change: −61 (3.) | 95 | M | 0.02
214 ↑ P Mod | Inflammatory change (%) | Mid (11) | Vehicle Percent change: 5 (7.) | 58 | M | NS
214 ↑ P Mod | Non-Inflammatory change (%) | Mid (11) | Benzoyl peroxide Percent change: −30 (4.) | 92 | M | 0.005
214 ↑ P Mod | Non-Inflammatory change (%) .01 vs clinda alone | Mid (11) | Clindamycin Percent change: −9 (6.) | 89 | M | 0.04
214 ↑ P Mod | Non-Inflammatory change (%) .01 vs clinda alone | Mid (11) | Clindamycin + benzoyl peroxide Percent change: −36 (4.) | 95 | M | 0.004
214 ↑ P Mod | Non-Inflammatory change (%) | Mid (11) | Vehicle Percent change: −11 (8.) | 58 | M | NS
229 ↑ P s Mod/sev | Inflammatory change (%) | Short (4) | Clindamycin hydrochloride (E-solve®) Percent change: −51 (34.) | 23 | M | NS
229 ↑ P s Mod/sev | Inflammatory change (%) Vs. clindamycin hydrochloride (Ionax^®^) | Mid (8) | Clindamycin hydrochloride (E-solve®) Percent change: −75 (22.) | 23 | M | 0.001
229 ↑ P s Mod/sev | Inflammatory change (%) | Short (4) | Clindamycin hydrochloride (Ionax®) Percent change: −70 (18.) | 16 | M | NS
229 ↑ P s Mod/sev | Inflammatory change (%) Vs. clindamycin hydrochloride (E-solve^®^) | Mid (8) | Clindamycin hydrochloride (Ionax®) Percent change: −83 (19.) | 16 | M | 0.001
229 ↑ P s Mod/sev | Inflammatory change (%) | Short (4) | Clindamycin phosphate (E-solve®) Percent change: 65 (32.) | 16 | M | NS
229 ↑ P s Mod/sev | Inflammatory change (%) Vs. clindamycin phosphate (Ionax^®^) | Mid (8) | Clindamycin phosphate (E-solve®) Percent change: −83 (22.) | 17 | M | NS
229 ↑ P s Mod/sev | Inflammatory change (%) | Short (4) | Clindamycin phosphate (Ionax®) Percent change: −66 (18.) | 21 | M | NS
229 ↑ P s Mod/sev | Inflammatory change (%)Vs. Clindamycin phosphate (e-solve) | Mid (8) | Clindamycin phosphate (Ionax®) Percent change: −81 (16.) | 20 | M | NS
229 ↑ P s Mod/sev | Inflammatory change (%) | Short (4) | E-solve® Percent change: −55 (37.) | 17 | M | NS
229 ↑ P s Mod/sev | Inflammatory change (%) Vs. Ionax® | Mid (8) | E-solve® Percent change: −78 (19.) | 19 | M | NS
229 ↑ P s Mod/sev | Inflammatory change (%) | Short (4) | Ionax® Percent change: −63 (28.) | 23 | M | NS
229 ↑ P s Mod/sev | Inflammatory change (%) Vs. E-solve® | Mid (8) | Ionax® Percent change: −76 (18.) | 23 | M | NS
233 ↑ P Mod/sev | Severity change (Michaelsson %) | Short (4) | Vehicle Raw measure: −25 (30.) | 14 | M | NS
233 ↑ P Mod/sev | Severity change (Michaelsson %) | Short (4) | Vitamin A palmitate Raw measure: −30 (27.) | 14 | M | NS
233 ↑ P Mod/sev | Severity change (Michaelsson %) | Short (4) | Zinc sulfate Raw measure: −64 (15.) | 15 | M | NS
233 ↑ P Mod/sev | Severity change (Michaelsson %) | Short (4) | Zinc sulfate + Vitamin A palmitate Raw measure: −58 (15.) | 18 | M | NS
239 ↓ P Mod/sev | Non-inflammatory change (%) | Mid (8) | Aluminum oxide Percent change: −19 | 10 | | NS
266 ↑ P Mod | Inflammatory (count) | Short (6) | Placebo Change*: −4 | 15 | NS
266 ↑ P Mod | Inflammatory (count) | Short (6) | Shankhabhasma vah Change*: −7 | 14 | NS
266 ↑ P Mod | Inflammatory (count) | Short (6) | Sookshama triphala Change*: −4 | 16 | NS
266 ↑ P Mod | Inflammatory (count) | Short (6) | Sunder vati Change*: −14 | 20 | 0.01
266 ↑ P Mod | Inflammatory (count) | Short (6) | Thiostanin Change*: −4 | 17 | NS
266 ↑ P Mod | Non-inflammatory (count) | Short (6) | Placebo Raw count: 46 (2.8) | 15 | NS
266 ↑ P Mod | Non-inflammatory (count) | Short (6) | Shankhabhasma vah Raw count: 46 (2.8) | 14 | NS
266 ↑ P Mod | Non-inflammatory (count) | Short (6) | Sookshama triphala Raw count: 46 (2.) | 16 | NS
266 ↑ P Mod | Non-inflammatory (count) | Short (6) | Sunder vati Raw count: 35 (4.) | 20 | 0.01
266 ↑ P Mod | Non-inflammatory (count) | Short (6) | Thiostanin Raw count: 45 (4.) | 17 | NS
302 ↓ P s Mild | Burning | Mid (10) | Tretinoin (0.01%) Raw measure: 1 | 20 | | NS
302 ↓ P s Mild | Burning | Mid (10) | Tretinoin (0.025%) Raw measure: 2 | 10 | | NS
302 ↓ P s Mild | Burning | Mid (10) | Tretinoin (0.05%) Raw measure: 2 | 10 | | NS
302 ↓ P s Mild | Erythema Only significant compared to patients asses .025% | Mid (10) | Tretinoin (0.01%) Raw measure: 1 | 20
302 ↓ P s Mild | Erythema | Mid (10) | Tretinoin (0.025%) Raw measure: 2 | 10 | | NS
302 ↓ P s Mild | Erythema | Mid (10) | Tretinoin (0.05%) Raw measure: 1 | 10 | | NS
302 ↓ P s Mild | Scaling | Mid (10) | Tretinoin (0.01%) Raw measure: 1 | 20
302 ↓ P s Mild | Scaling Only significant in does assess with respect to .025 | Mid (10) | Tretinoin (0.025%) Raw measure: 2 | 10 | M | 0.05
302 ↓ P s Mild | Scaling | Mid (10) | Tretinoin (0.05%) Raw measure: 2 | 10 | | NS
302 ↓ P s Mild | Comedones (count) | Mid (10) | Tretinoin (0.01%) Change*: −7 | 20 | M | M
302 ↓ P s Mild | Comedones (count) | Mid (10) | Tretinoin combined Change*: −7 | 20 | | NS
302 ↓ P s Mild | Inflammatory (count) | Mid (10) | Tretinoin (0.01%) Change*: −4 | 20 | | 0.05
302 ↓ P s Mild | Inflammatory (count) | Mid (10) | Tretinoin combined Change*: −7 | 20 | M | M
302 ↓ P s Mild | Comedones (improvement) | Short (6) | Tretinoin (0.01%) Raw measure: 13 | 20 | | 0.05
302 ↓ P s Mild | Comedones (improvement) | Mid (10) | Tretinoin (0.01%) Raw measure: 14 | 20 | M | M
302 ↓ P s Mild | Comedones (improvement) | Short (6) | Tretinoin combined Raw measure: 10 | 20 | | 0.05
302 ↓ P s Mild | Comedones (improvement) | Mid (10) | Tretinoin combined Raw measure: 12 | 20 | M | M
302 ↓ P s Mild | Inflammatory (improvement) | Short (6) | Tretinoin (0.01%) Raw measure: 13 | 20 | M | M
302 ↓ P s Mild | Inflammatory (improvement) | Mid (10) | Tretinoin (0.01%) Raw measure: 14 | 20 | | 0.05
302 ↓ P s Mild | Inflammatory (improvement) | Short (6) | Tretinoin combined Raw measure: 12 | 20 | M | M
302 ↓ P s Mild | Inflammatory (improvement) | Mid (10) | Tretinoin combined Raw measure: 13 | 20 | | 0.05
349 ↓ P Mild/mod | Total change (%) 2-factor ANOVA | Mid (8) | Ibuprofen + placebo Percent change: −26 (52.) | 14 | | 0.05
349 ↓ P Mild/mod | Total change (%) 2-factor ANOVA | Mid (8) | Placebo Percent change: −16 (44.) | 16 | | NS
349 ↓ P Mild/mod | Total change (%) 2-factor ANOVA | Mid (8) | Tetracycline + placebo Percent change: −26 (36.) | 15 | | 0.05
349 ↓ P Mild/mod | Total lesion (count) | Short (4) | Ibuprofen + placebo Change*: −8 | 14
349 ↓ P Mild/mod | Total lesion (count) | Short (4) | Placebo Change*: −1 | 16
349 ↓ P Mild/mod | Total lesion (count) | Short (4) | Tetracycline + placebo Change*: −3 | 15

TRIAL: ↑↓ refer to the presence of positive or negative methodological features (see Summary Table). “Mild/mod,” etc., refer to our assessment of entry severity of study patients. “P” refers to parallel study, “S,” to split face design. TREATMENT: “Percent change” indicates an outcome derived from individual final and baseline measures; “Percent change*” indicates that we calculated a group-based percentage change; “Change” indicates raw difference from baseline; “Change*” indicates calculated change; “Measure” indicates an outcome measure with no baseline comparison. SD indicates standard deviation, SS, sample size (with * means calcuted as total sample size divided by number of arms), and WITHIN P, P-value with respect to baseline.“M” means no P-value available. BETWEENP-VALUE: a comparison between Treatment and another treatment. “Sig” indicates authors' statement regarding statistical significance, without quantitation.

Evidence Table MULTI.3. DISCRETE Outcomes of MULTI-ARM Trials

Trial | Discrete Outcome Name (Units) Comments re Between P-value | Follow up | Treatment | Between P-value
97 ↑ P Mild/mod | Overall change/investigator | Short (4) | Benzoyl peroxide improved 31 Same 14 worse 3
97 ↑ P Mild/mod | Overall change/investigator | Short (4) | Benzoyl peroxide + chlorhydroxyquinoline improved 35 Same 11 worse 2
97 ↑ P Mild/mod | Overall change/investigator | Short (4) | Vehicle improved 16 Same 18 worse 15
119 ↑ P s | Discontinuation due to side effects | Short (3) | Adapalene discontinued 0
119 ↑ P s | Discontinuation due to side effects | Short (3) | Petrolatum discontinued 1
119 ↑ P s | Discontinuation due to side effects | Short (3) | Tretinoin (0.01% gel) discontinued 16
119 ↑ P s | Discontinuation due to side effects | Short (3) | Tretinoin (0.025% cream) discontinued 5
119 ↑ P s | Discontinuation due to side effects | Short (3) | Tretinoin (0.025% gel) discontinued 18
119 ↑ P s | Discontinuation due to side effects | Short (3) | Tretinoin (0.05% cream) discontinued 13
119 ↑ P s | Discontinuation due to side effects | Short (3) | Tretinoin (0.1% cream) discontinued 25
120 ↑ P s | Discontinuation due to side effects | Short (3) | Adapalene discontinued 0
120 ↑ P s | Discontinuation due to side effects | Short (3) | Petrolatum discontinued 0
120 ↑ P s | Discontinuation due to side effects | Short (3) | Tretinoin (0.1% cream) discontinued 7
120 ↑ P s | Discontinuation due to side effects | Short (3) | Tretinoin (0.025% cream) discontinued 0
120 ↑ P s | Discontinuation due to side effects | Short (3) | Tretinoin (0.05% cream) discontinued 3
120 ↑ P s | Discontinuation due to side effects | Short (3) | Tretinoin (0.1% gel) discontinued 2
132 ↑ P Sev | Overall change | Mid (12) | Placebo worse 1 No change 4 better 1
132 ↑ P Sev | Overall change | Mid (12) | Spironolactone (100) worse 0 No change 3 better 2
132 ↑ P Sev | Overall change | Mid (12) | Spironolactone (150) worse 0 No change 2 better 4
132 ↑ P Sev | Overall change | Mid (12) | Spironolactone (200) worse 0 No change 1 better 3
132 ↑ P Sev | Overall change | Mid (12) | Spironolactone (50) worse 0 No change 4 better 1
132 ↑ P Sev | Overall change/patient | Mid (12) | Placebo worse 1 No change 4 better 1
132 ↑ P Sev | Overall change/patient | Mid (12) | Spironolactone (100) worse 0 No change 1 better 4
132 ↑ P Sev | Overall change/patient | Mid (12) | Spironolactone (150) worse 0 No change 1 better 5
132 ↑ P Sev | Overall change/patient | Mid (12) | Spironolactone (200) worse 0 No change 0 better 4
132 ↑ P Sev | Overall change/patient | Mid (12) | Spironolactone (50) worse 1 No change 2 better 2
132 ↑ P Sev | Overall change/photo | Mid (12) | Placebo worse 3 No change 2 better 1
132 ↑ P Sev | Overall change/photo | Mid (12) | Spironolactone (100) worse 1 No change 1 better 3
132 ↑ P Sev | Overall change/photo | Mid (12) | Spironolactone (150) worse 0 No change 1 better 5
132 ↑ P Sev | Overall change/photo | Mid (12) | Spironolactone (200) worse 1 No change 0 better 3
132 ↑ P Sev | Overall change/photo | Mid (12) | Spironolactone (50) worse 1 No change 1 better 3
149 ↓ P Mild/mod/sev | Inflammatory changes (Witkowski discretized %) | Mid (10) | Benzoyl peroxide (10%) Excellent (>75%) 18 Good (>50%) 10 Moderate + Poor (>0%) 3 | NS
149 ↓ P Mild/mod/sev | Inflammatory changes (Witkowski discretized %) | Mid (10) | Benzoyl peroxide (5%) Excellent (>75%) 20 Good (>50%) 14 Moderate + Poor (>0%) 6 | NS
149 ↓ P Mild/mod/sev | Inflammatory changes (Witkowski discretized %) | Mid (10) | Tretinoin Excellent (>75%) 23 Good (>50%) 4 Moderate + Poor (>0%) 4 | NS
149 ↓ P Mild/mod/sev | Non-inflammatory changes (Witkowski discretized %) | Mid (10) | Benzoyl peroxide (10%) Excellent (>75%) 25 Good (>50%) 8 Moderate + Poor (>0%) 1
149 ↓ P Mild/mod/sev | Non-inflammatory changes (Witkowski discretized %) | Mid (10) | Benzoyl peroxide (5%) Excellent (>75%) 27 Good (>50%) 10 Moderate + Poor (>0%) 4
149 ↓ P Mild/mod/sev | Non-inflammatory changes (Witkowski discretized %) | Mid (10) | Tretinoin Excellent (>75%) 32 Good (>50%) 2 Moderate + Poor (>0%) 2
149 ↓ P Mild/mod/sev | Overall change (Witkowski discretized %) | Mid (10) | Benzoyl peroxide (10%) Excellent (>75%) 26 Good (>50%) 7 Moderate + Poor (>0%) 1 | NS
149 ↓ P Mild/mod/sev | Overall change (Witkowski discretized %) | Mid (10) | Benzoyl peroxide (5%) Excellent (>75%) 28 Good (>50%) 9 Moderate + Poor (>0%) 4 | NS
149 ↓ P Mild/mod/sev | Overall change (Witkowski discretized %) | Mid (10) | Tretinoin Excellent (>75%) 32 Good (>50%) 2 Moderate + Poor (>0%) 2 | 0.01
149 ↓ P Mild/mod/sev | Side effects/Withdrawal | Mid (10) | Benzoyl peroxide (10%) Allergy 1 Severe irritation reaction 12 Toxic reation 0 | 0.05
149 ↓ P Mild/mod/sev | Side effects/Withdrawal | Mid (10) | Benzoyl peroxide (10%) Allergy 1 Severe irritation reaction 12 Toxic reation 0 | 0.05
149 ↓ P Mild/mod/sev | Side effects/Withdrawal | Mid (10) | Benzoyl peroxide (5%) Allergy 2 Severe irritation reaction 2 Toxic reation 0 | 0.05
149 ↓ P Mild/mod/sev | Side effects/Withdrawal | Mid (10) | Benzoyl peroxide (5%) Allergy 2 Severe irritation reaction 2 Toxic reation 0 | 0.05
149 ↓ P Mild/mod/sev | Side effects/Withdrawal | Mid (10) | Tretinoin Allergy 0 Severe irritation reaction 11 Toxic reation 0 | 0.05
149 ↓ P Mild/mod/sev | Side effects/Withdrawal | Mid (10) | Tretinoin Allergy 0 Severe irritation reaction 11 Toxic reation 0 | 0.05
177 ↑ P | Clinical assessed facial lesions | Mid (12) | Benzoyl peroxide resolved 4 Much better 8 better 6 same 3 worse 2
177 ↑ P | Clinical assessed facial lesions | Mid (12) | Hydroxyquinoline + benzoyl peroxide resolved 6 Much better 11 better 2 same 1
177 ↑ P | Clinical assessed facial lesions | Mid (12) | Vehicle resolved 4 Much better 10 better 4 same 6 worse 1
177 ↑ P | Clinical assessment back lesions | Mid (12) | Benzoyl peroxide resolved 2 Much better 2 better 5 same 4 worse
177 ↑ P | Clinical assessment back lesions | Mid (12) | Hydroxyquinoline + benzoyl peroxide resolved 4 Much better 4 better 5 same 3
177 ↑ P | Clinical assessment back lesions | Mid (12) | Vehicle resolved 3 Much better 3 better 4 same 4
177 ↑ P | Clinical assessment chest lesions | Mid (12) | Benzoyl peroxide resolved 1 Much better 4 better 3 same 3
177 ↑ P | Clinical assessment chest lesions | Mid (12) | Hydroxyquinoline + benzoyl peroxide resolved 2 Much better 3 better 3 same 2
177 ↑ P | Clinical assessment chest lesions | Mid (12) | Vehicle resolved 3 Much better 2 better 3 same 3
177 ↑ P | Greasiness | | Benzoyl peroxide absent 7 Slight 13 moderate 4 marked
177 ↑ P | Greasiness | | Hydroxyquinoline + benzoyl peroxide absent 10 Slight 10 moderate 1 marked 1
177 ↑ P | Greasiness | | Vehicle absent 7 Slight 15 moderate 6 marked
214 ↑ P Mod | Local side effects | Mid (11) | Benzoyl peroxide erythema 13 Peeling 19 dryness 7 burning 1 pruritis 2 | NS
214↑ P Mod | Local side effects | Mid (11) | Clindamycin erythema 6 Peeling 7 dryness 5 burning 0 pruritis 1 | NS
214↑ P Mod | Local side effects | Mid (11) | Clindamycin + benzoyl peroxide erythema 7 Peeling 21 dryness 8 burning 2 pruritis 2 | NS
214↑ P Mod | Local side effects | Mid (11) | Vehicle erythema 6 Peeling 9 dryness 2 burning 1 pruritis 3 | NS
214↑ P Mod | Overall change/physician | Mid (11) | Benzoyl peroxide excellent or good 38 Good, fair or worse 54 | 0.01
214↑ P Mod | Overall change/physician | Mid (11) | Clindamycin excellent or good 32 Good, fair or worse 57 | 0.01
214↑ P Mod | Overall change/physician | Mid (11) | Clindamycin + benzoyl peroxide excellent or good 63 Good, fair or worse 32 | 0.01
214↑ P Mod | Overall change/physician | Mid (11) | Vehicle excellent or good 6 Good, fair or worse 52 | NS
233 ↑ P Mod/sev | Side effects | Mid (12) | Vehicle dry skin 0
233 ↑ P Mod/sev | Side effects | Mid (12) | Vitamin A palmitate dry skin 0
233 ↑ P Mod/sev | Side effects | Mid (12) | Zinc sulfate dry skin 4
233 ↑ P Mod/sev | Side effects | Mid (12) | Zinc sulfate + Vitamin A palmitate dry skin 4
238 ↓ P Mod/sev | Overall change/physician | Mid (8) | Erythromycin excellent (75% or greater) 1 Good (50-74%) 8 fair (25-49%) 7 poor (<24%) 4
238 ↓ P Mod/sev | Overall change/physician | Mid (8) | Erythromycin + tretinoin excellent (75% or greater) 5 Good (50-74%) 10 fair (25-49%) 5 poor (<24%) 0
238 ↓ P Mod/sev | Overall change/physician | Mid (8) | Tretinoin excellent (75% or greater) 5 Good (50-74%) 5 fair (25-49%) 6 poor (<24%) 4
238 ↓ P Mod/sev | Overall change/physician | Mid (8) | Vehicle excellent (75% or greater) 0 Good (50-74%) 2 fair (25-49%) 6 poor (<24%) 12
287 ↓ P | Overall change/physician | Long (16) | Hydrocortisone improved 14 Unimproved 10
287 ↓ P | Overall change/physician | Long (16) | Neomycin improved 10 Unimproved 10
287 ↓ P | Overall change/physician | Long (16) | Resorcinol improved 17 Unimproved 7
287 ↓ P | Overall change/physician | Long (16) | Resorcinol + neomycin + hydrocortisone F + sulfur improved 21 Unimproved 11
287 ↓ P | Overall change/physician | Long (16) | Sulfur improved 11 Unimproved 12
287 ↓ P | Overall change/physician | Long (16) | Vehicle improved 14 Unimproved 12
287 ↓ P | Side effects | Long (16) | Hydrocortisone itching/erythema 2
287 ↓ P | Side effects | Long (16) | Neomycin itching/erythema 0
287 ↓ P | Side effects | Long (16) | Resorcinol itching/erythema 3
287 ↓ P | Side effects | Long (16) | Resorcinol + neomycin + hydrocortisone F + sulfur itching/erythema 2
287 ↓ P | Side effects | Long (16) | Sulfur itching/erythema 5
287 ↓ P | Side effects | Long (16) | Vehicle itching/erythema 2
288 ↓ P | Overall change/physician | Long (16) | Hydrocortisone improved 11 Unimproved 10
288 ↓ P | Overall change/physician | Long (16) | Hydrocortisone + sulfur improved 14 Unimproved 10
288 ↓ P | Overall change/physician | Long (16) | Neomycin improved 12 Unimproved 12
288 ↓ P | Overall change/physician | Long (16) | Neomycin + resorcinol + hydrocortisone + sulfur improved 12 Unimproved 11
288 ↓ P | Overall change/physician | Long (16) | Neomycin + sulfur improved 12 Unimproved 11
288 ↓ P | Overall change/physician | Long (16) | Resorcinol improved 12 Unimproved 13
288 ↓ P | Overall change/physician | Long (16) | Sulfur improved 12 Unimproved 11
288 ↓ P | Overall change/physician | Long (16) | Vehicle improved 12 Unimproved 13
288 ↓ P | Side effects | Long (16) | Hydrocortisone itching/erythema 0
288 ↓ P | Side effects | Long (16) | Hydrocortisone + sulfur itching/erythema 2
288 ↓ P | Side effects | Long (16) | Neomycin itching/erythema 3
288 ↓ P | Side effects | Long (16) | Neomycin + resorcinol + hydrocortisone + sulfur itching/erythema 1
288 ↓ P | Side effects | Long (16) | Neomycin + sulfur itching/erythema 2
288 ↓ P | Side effects | Long (16) | Resorcinol itching/erythema 3
288 ↓ P | Side effects | Long (16) | Sulfur itching/erythema 3
288 ↓ P | Side effects | Long (16) | Vehicle itching/erythema 0
302 ↓ P s Mild | Acne flare-up | | Tretinoin (0.01%) left study 1 No flare-up 19
302 ↓ P s Mild | Acne flare-up | | Tretinoin combined left study 3 No flare-up 17
340 ↑ P Mod/sev | Inter-treatment severity comparison | | Erythromycin proprionate more effective than placebo 5
340 ↑ P Mod/sev | Inter-treatment severity comparison | | Erythromycin stearate more effective than placebo 8
340 ↑ P Mod/sev | Inter-treatment severity comparison | | Placebo more effective than placebo 5
340 ↑ P Mod/sev | Inter-treatment severity comparison | | Tetracycline phosphate more effective than placebo 13
340 ↑ P Mod/sev | Inter-treatment severity comparison | | Tetracycline-citric acid more effective than placebo 13
340 ↑ P Mod/sev | Inter-treatment severity comparison | | Tetracycline-novobiocin more effective than placebo 3
340 ↑ P Mod/sev | Inter-treatment severity comparison | | Triacetyl-oleandomycin more effective than placebo 12
349 ↓ P Mild/mod | Improvement | Mid (8) | Ibuprofen + placebo > 50% improvement 21 0-50% improvement 58 Worsening 21
349 ↓ P Mild/mod | Improvement | Mid (8) | Placebo > 50% improvement 12 0-50% improvement 68 Worsening 20
349 ↓ P Mild/mod | Improvement | Mid (8) | Tetracycline + placebo > 50% improvement 25 0-50% improvement 55 Worsening 20
349 ↓ P Mild/mod | Side effects overall | | Ibuprofen + placebo Withdrawal 1 Some symptoms 3 No symptoms 12
349 ↓ P Mild/mod | Side effects overall | | Placebo Withdrawal 1 Some symptoms 2 No symptoms 15
349 ↓ P Mild/mod | Side effects overall | | Tetracycline + placebo Withdrawal 1 Some symptoms 6 No symptoms 10
349 ↓ P Mild/mod | Side effects specific | | Ibuprofen + placebo Nausea 1 Vomiting 1 Diarrhea 1 Cramps/fullness 2 Other 1
349 ↓ P Mild/mod | Side effects specific | | Placebo Nausea 1 Vomiting 1 Diarrhea 1 Cramps/fullness 0 Other 0
349 ↓ P Mild/mod | Side effects specific | | Tetracycline + placebo Nausea 2 Vomiting 1 Diarrhea 0 Cramps/fullness 4 Other 1
350 ↑ P s Sev | Overall change/patient [acne conglobata] | Long (24) | Grenz ray + hexachlorophene improved 17 Worse 8
350 ↑ P s Sev | Overall change/patient [acne conglobata] | Long (24) | Sham rays + hexachlorophene improved 17 Worse 8
350 ↑ P s Sev | Overall change/patient [acne vulgaris] | Long (24) | Grenz ray + hexachlorophene yes 38 No 7
350 ↑ P s Sev | Overall change/patient [acne vulgaris] | Long (24) | Grenz rays yes 4 No 19
350 ↑ P s Sev | Overall change/patient [acne vulgaris] | Long (24) | Sham rays + hexachlorophene yes 38 No 7
350 ↑ P s Sev | Overall change/patient [acne vulgaris] | Long (24) | Untreated yes 4 No 19
350 ↑ P s Sev | Pigmentation | Long (24) | Grenz ray + hexachlorophene mentioned 55 Not mentioned 11
350 ↑ P s Sev | Pigmentation | Long (24) | Sham rays + hexachlorophene mentioned 55 Not mentioned 11
350 ↑ P s Sev | Severity change/patient-treated side [acne vulgaris] | Long (24) | Grenz ray + hexachlorophene treatment side better 19 Placebo side better 26 no change 0
350 ↑ P s Sev | Severity change/patient-treated side [acne vulgaris] | Long (24) | Grenz rays treatment side better 9 Placebo side better 11 no change 5
350 ↑ P s Sev | Severity change/patient-treated side [acne vulgaris] | Long (24) | Sham rays + hexachlorophene treatment side better 19 Placebo side better 26 no change
350 ↑ P s Sev | Severity change/patient-treated side [acne vulgaris] | Long (24) | Untreated treatment side better 9 Placebo side better 11 no change 5

↑↓ refer to the presence of positive or negative methodological features (see Summary Table). “mild/mod,” etc., refer to our assessment of entryseverity of study patients. “P” refers to parallel study,“S,” to split face design. BETWEEN P-value indicates a comparison among arms of the study.