# Index to Evidence Tables

Comparison index ^a^ | Secondary ^b^ | Target arm | Comparator arm
M.04.04 | | 16-epiestriol-3-allyl ether (oral) | Placebo (oral)
A.01.01 | | Acidic syndet bar (topical) | Soap (topical)
E.01.01 | | Adapalene (0.03%) (topical) | Adapalene (0.1%) (topical)
E.01.02 | | Adapalene (topical) | Tretinoin (topical)
K.01.01 | K.02.04 | Alitretinoin (oral) | Isotretinoin(oral)
B.07.02 | | Aluminum chlorhydroxide/sulphur (topical) | Vehicle (topical)
B.07.03 | N.02.06 | Aluminum chlorhydroxide/sulphur (topical) | Neomycin/methylprednisolone (topical)
B.07.01 | | Aluminum chloride (topical) | Vehicle (topical)
A.01.015 | | Aluminum oxide (topical) | Other cleansers (topical)
N.01.01 | | Ayurvedic remedies (oral) | Placebo (oral)
B.01.01 | | Azelaic acid (topical) | Vehicle (topical)
B.01.02 | | Azelaic acid (topical) | Benzoyl peroxide (topical)
B.01.03 | E.05.04 | Azelaic acid (topical) | Tretinoin (topical)
B.01.04 | H.08.07 | Azelaic acid (topical) | Tetracycline (oral)
B.02.01 | E.05.04 | Azelaic acid/glycolic acid (topical) | Tretinoin (topical)
D.01.01 | | Benzoyl peroxide (topical) | Vehicle (topical)
D.01.02 | B.01.02 | Benzoyl peroxide (topical) | Azelaic acid (topical)
D.01.03 | | Benzoyl peroxide (topical) | Gluconolactone (topical)
D.01.04 | | Benzoyl peroxide (topical) | Salicylic acid (topical)
D.01.05 | | Benzoyl peroxide (topical) | Sulphur/resorcinol (topical)
D.01.06 | C.01.06 | Benzoyl peroxide (topical) | Clindamycin phosphate (topical)
D.01.07 | C.05.01 | Benzoyl peroxide (topical) | Meclocycline (topical)
D.01.08 | C.08.03 | Benzoyl peroxide (topical) | Tetracycline (topical)
D.01.09 | | Benzoyl peroxide (topical) | Benzoyl peroxide (topical)
D.01.10 | | Benzoyl peroxide (topical) | Benzoyl peroxide/urea (topical)
D.01.11 | D.06.01 | Benzoyl peroxide (topical) | Meclocycline/benzoyl peroxide (topical)
D.01.12 | D.07.02 | Benzoyl peroxide (topical) | Metronidazole/benzoyl peroxide (topical)
D.01.13 | E.05.02 | Benzoyl peroxide (topical) | Tretinoin (topical)
D.01.14 | E.06.02 | Benzoyl peroxide (topical) | Vitamin A (topical)
D.01.15 | H.06.02 | Benzoyl peroxide (topical) | Oxytetracycline (oral)
D.01.16 | E.02.02 | Benzoyl peroxide (topical) | Isotretinoin (oral)
D.01.17 | D.08.01 | Benzoyl peroxide (topical) | Miconazole/benoyl peroxide (topical)
D.01.18 | N.04.05 | Benzoyl peroxide (topical) | Chloramphenicol/hydrocortisone/sulfur (topical)
D.01.19 | N.01.03 | Benzoyl peroxide (topical) | Isolutrol (topical)
D.03.02 | | Benzoyl | Benzoyl peroxide/hydroxyquinolone (topical)
D.03.03 | | Benzoyl | Benzoyl peroxide/chlorhydroxyquinolone (topical)
D.03.01 | | Benzoyl peroxide/glycolic acid/zinc sulphur | Placebo (topical)
D.03.04 | | Benzoyl peroxide/sulphur (topical) | Sulphur (topical)
D.02.01 | N.04.03 | Chloramphenical/sulpur (topical) | Chloramphenical/hydrocortisone/sulpur (topical)
N.04.01 | | Chloramphenicol/hydrocortisone | Vehicle (topical)
N.04.06 | E.05.09 | Chloramphenicol/hydrocortisone (topical) | Tretinoin (topical)
N.04.03 | | Chloramphenicol/hydrocortisone/sulphur | Chloramphenicol/sulphur (topical)
N.04.04 | | Chloramphenicol/hydrocortisone/sulphur | Hydrocortisone/sulphur (topical)
N.04.05 | | Chloramphenicol/hydrocortisone/sulphur | Benzoyl peroxide (topical)
N.06.01 | | Cimetidine [men] (oral) | Cimetidine [women] (oral)
H.01.01 | | Clindamycin (oral) | Placebo (oral)
H.01.02 | | Clindamycin (oral) | Tetracycline (oral)
C.01.01 | | Clindamycin (topical) | Vehicle (topical)
C.01.02 | | Clindamycin (topical) | Nicotinamide (topical)
C.01.03 | | Clindamycin (topical) | Clindamycin (topical)
C.01.04 | | Clindamycin (topical) | Erythromycin (topical)
C.01.05 | | Clindamycin (topical) | Tetracycline (topical)
C.01.07 | | Clindamycin (topical) | Clindamycin/benzoyl peroxide (topical)
C.01.08 | D.05.02 | Clindamycin (topical) | Erythromycin/benzoyl peroxide (topical)
C.01.09 | N.08.03 | Clindamycin (topical) | Erythromycin/zinc (topical)
C.01.06 | | Clindamycin phosphate (topical) | Benzoyl peroxide (topical)
C.02.01 | | Clindamycin/benzoyl peroxide (topical) | Vehicle (topical)
C.02.02 | C.01.07 | Clindamycin/benzoyl peroxide (topical) | Clindamycin (topical)
C.02.03 | | Clindamycin/benzoyl peroxide (topical) | Benzoyl peroxide (topical)
D.04.01 | | Clindamycin/benzoyl peroxide (topical) | Vehicle (topical)
D.04.02 | C.01.07 | Clindamycin/benzoyl peroxide (topical) | Clindamycin (topical)
D.04.03 | C.02.03 | Clindamycin/benzoyl peroxide (topical) | Benzoyl peroxide (topical)
N.02.01 | | Clobetasol (topical) | Vehicle (topical)
N.05.02 | | Comedone extraction (cheeks/forehead) | Untreated
N.06.02 | | Contingent contract/benzoyl peroxide (topical) | Benzoyl peroxide (topical)
H.07.01 | | Cotrimoxazole (oral) | Placebo (oral)
I.01.01 | | Cotrimoxazole (oral)/sulphur/resorcinol | Cotrimoxazole (oral)
I.01.02 | | Cotrimoxazole (oral)/sulphur/resorcinol | Cotrimoxazole (oral)/tretinoin
J.01.01 | | Cotrimoxazole (oral)/Tretinoin (topical) | Cotrimoxazole (oral)
M.01.06 | | Cyproterone (2 mg)/ethinyl estradiol (oral) | Cyproterone (0.05 mg)/ethinyl estradiol (oral)
M.01.09 | | Cyproterone (50)/ethinyl estradiol (oral) | Norethisterone/placebo/ethinyl estradiol (oral)
M.01.01 | | Cyproterone (topical) | Vehicle (topical)
M.01.01 | | Cyproterone/ethinyl estradiol (0.035) (oral) | Vehicle (topical)
M.01.04 | | Cyproterone/ethinyl estradiol (0.035) (oral) | Cyproterone (topical)
M.01.07 | | Cyproterone/ethinyl estradiol (0.035) (oral) | Desogestrel/ethinyl estradiol (oral)
M.01.08 | | Cyproterone/ethinyl estradiol (0.035) (oral) | Levonorgestrel/ethinyl estradiol (0.030) (oral)
M.01.05 | | Cyproterone/ethinyl estradiol (0.05) (oral) | Cyproterone/ethinyl estradiol (0.035) (oral)
M.01.02 | | Cyproterone/ethinyl estradiol (oral) | Minocycline hydrochloride (oral)
M.01.03 | | Cyproterone/ethinyl estradiol (oral) | Tetracycline (oral)
H.09.01 | | Dapsone (oral) | Placebo (oral)
M.04.01 | | Delta-0.2%-chlormadione (oral) | Placebo (oral)
M.04.03 | | Delta-0.2%-chlormadione (oral) | Delta-5%-chlormadione (oral)
M.04.02 | | Delta-5%-chlormadione (oral) | Placebo (oral)
H.02.01 | | Demethylchlortetracycline (oral) | Placebo (oral)
H.02.02 | | Demethylchlortetracycline (oral) | Phenethicillin (oral)
H.02.03 | | Demethylchlortetracycline (oral) | Tetracycline (oral)
M.02.01 | | Desogestrel/ethinyl estradiol (oral) | Gestodene/ethinyl estradiol (oral)
M.02.02 | | Desogestrel/ethinyl estradiol (oral) | Levonorgestrel/ethinyl estradiol (oral)
H.03.01 | | Doxycycline (oral) | Placebo (oral)
H.03.02 | | Doxycycline (oral) | Fusidic acid cream (topical)
H.03.03 | | Doxycycline (oral) | Erythromycin stearate (oral)
H.03.04 | | Doxycycline (oral) | Minocycline (oral)
M.04.05 | | Epiestriol (oral) | Placebo (oral)
H.04.01 | H.03.03 | Erythromycin (oral) | Doxycycline (oral)
H.04.03 | | Erythromycin (oral) | Tetracycline (oral)
H.04.04 | | Erythromycin (oral) | Triacetyl-oleandomycin (oral)
C.03.01 | | Erythromycin (topical) | Vehicle (topical)
C.03.02 | C.01.04 | Erythromycin (topical) | Clindamycin (topical)
C.03.025 | | Erythromycin (topical) | Benzoyl peroxide (topical)
C.03.03 | N.08.02 | Erythromycin (topical) | Erythromycin/zinc (topical)
H.04.02 | | Erythromycin base (oral) | Erythromycin stearate (oral)
D.05.01 | | Erythromycin/benzoyl peroxide (topical) | Placebo (topical)
D.05.015 | | Erythromycin/benzoyl peroxide (topical) | Benzoyl peroxide (topical)
D.05.02 | | Erythromycin/benzoyl peroxide (topical) | Clindamycin phosphate (topical)
D.05.03 | | Erythromycin/benzoyl peroxide (topical) | Benzoyl peroxide/glycolic acid/zinc sulphur (topical)
D.05.04 | | Erythromycin/benzoyl peroxide (topical) | Erythromycin/zinc (topical)
D.05.05 | N.06.03 | Erythromycin/benzoyl peroxide (topical) | Group therapy
D.05.06 | N.06.03 | Erythromycin/benzoyl peroxide (topical) | Relaxation training/erythromycin/benzoyl peroxide
N.05.03 | | Fulguration | Tretinoin (topical)
N.05.04 | | Fulguration | Electrocautery
C.04.01 | | Fusiden (topical) | Vehicle (topical)
C.04.02 | H.03.02 | Fusidic acid (topical) | Doxycycline (oral)
C.04.03 | H.09.05 | Fusidic acid (topical) | Sodium fusidate (oral)
N.03.01 | | Gamma-globulin (parenteral) | Placebo (parenteral)
B.07.04 | | Gluconolactone (topical) | Vehicle (topical)
B.07.05 | D.01.03 | Gluconolactone (topical) | Benzoyl peroxide (topical)
B.07.06 | | Glycolic acid/soybean liposome (topical) | Soybean liposome (topical)
N.05.01 | | Grenz rays | Sham rays
N.01.02 | | Gugulipid (oral) | Tetracycline (oral)
A.01.02 | C.09.02 | Hexachlorophene (topical) | Triclosan (topical)
N.06.04 | | Hydrochlorthiazide (oral) | Placebo (oral)
N.02.03 | | Hydrocortisone (topical) | Hydrocortisone/sulfur (topical)
N.04.02 | | Hydrocortisone/buttoxethyl | Vehicle (topical)
N.02.02 | | Hydrocortisone/neomycin/sulfur/resorcinol | Components (topical)
N.06.045 | | Ibuprofen/tetracycline (oral) | Placebo (oral)
M.04.06 | | Inocoterone acetate (oral) | Placebo (oral)
N.01.03 | | Isolutrol (topical) | Benzoyl peroxide (topical)
E.02.03 | | Isotretinoin (0.05% topical) | Isotretinoin (0.1% topical)
K.02.01 | | Isotretinoin (oral) | Placebo (oral)
K.02.02 | | Isotretinoin (oral) | Dapsone (oral)
K.02.03 | | Isotretinoin (oral) | Tetracycline HCl (oral)
K.02.04 | | Isotretinoin (oral) | Altretinoin (oral)
K.02.05 | | Isotretinoin (oral) | Etretinate (oral)
K.02.06 | | Isotretinoin (oral) | Isotretinoin (oral)
E.02.01 | | Isotretinoin (topical) | Vehicle (topical)
E.02.02 | | Isotretinoin (topical) | Benzoyl peroxide (topical)
E.02.04 | | Isotretinoin (topical) | Tretinoin (topical)
B.06.01 | | Komed (sulphur/salicylic acid/resorcinol) | Placebo (topical)
B.06.02 | | Komed (sulphur/salicylic acid/resorcinol) | Proprietary formula (sulphur/salicylic
M.04.07 | M.01.08 | Levonorgestrel/ethinyl estradiol (oral) | Cyproterone/ethinyl estradiol (oral)
C.05.01 | | Meclocycline (topical) | Benzoyl peroxide (topical)
C.05.02 | H.08.06 | Meclocycline (topical) | Tetracycline (oral)
C.05.005 | | Meclocycline (topical) | Inert (topical)
D.06.01 | | Meclocycline/benzoyl peroxide (topical) | Benzoyl peroxide (topical)
N.02.04 | | Methylprednisolone/neomycin (topical) | Vehicle (topical)
N.02.06 | | Methylprednisolone/neomycin (topical) | Aluminum chlorhydroxide/sulphur (topical)
N.02.07 | E.05.08 | Methylprednisolone/neomycin (topical) | Tretinoin (topical)
N.02.05 | | Methylprednisolone/neomycin/sulphur (topical) | Vehicle (topical)
C.06.01 | | Metronidazole (topical) | Placebo (topical)
D.07.01 | | Metronidazole/benzoyl peroxide (topical) | Vehicle (topical)
D.07.02 | | Metronidazole/benzoyl peroxide (topical) | Benzoyl peroxide (topical)
D.07.03 | H.06.03 | Metronidazole/benzoyl peroxide (topical) | Oxytetracycline (oral)
D.08.01 | | Miconazole/benzoyl peroxide (topical) | Benzoyl peroxide (topical)
D.0802 | | Miconazole/benzoyl peroxide (topical) | Isoconazole/benzoyl peroxide (topical)
H.05.01 | | Minocycline (oral) | Placebo (oral)
H.05.02 | | Minocycline (oral) | Clindamycin phosphate (topical)
H.05.03 | H.03.04 | Minocycline (oral) | Doxycycline (oral)
H.05.04 | | Minocycline (oral) | Tetracycline (oral)
E.03.02 | | Motretinide (bid) (topical) | Motretinide (qd) (topical)
E.03.01 | | Motretinide (topical) | Vehicle (topical)
E.03.03 | | Motretinide (topical) | Tretinoin (topical)
C.07.01 | | Neomycin (topical) | Keratolytics/anti-inflammatory (topical)
B.07.07 | C.01.02 | Nicotinamide (topical) | Clindamycin (topical)
M.04.08 | M.01.09 | Norethisterone/placebo/ethinyl estradiol (oral) | Cyproterone cyproterone/ethinyl estradiol (oral)
M.04.09 | | Norgestimate/ethinyl estradiol (oral) | Placebo (oral)
N.01.04 | | Ocimum basilicum (topical) | Tetracycline (oral)
H.04.06 | | Oleandomycin (oral) | Triacetyl-oleandomycin (oral)
H.06.01 | | Oxytetracycline (oral) | Placebo (oral)
H.06.02 | | Oxytetracycline (oral) | Benzoyl peroxide (topical)
H.06.03 | | Oxytetracycline (oral) | Benzoyl peroxide/metronidazole (topical)
H.06.04 | E.06.03 | Oxytetracycline (oral) | Vitamin A (topical)
H.06.05 | | Oxytetracycline (oral) | Tetracycline (topical)
H.06.05 | | Oxytetracycline (oral) | Cotrimoxazole (oral)
H.06.06 | | Oxytetracycline (oral) | Cotrimoxazole (oral)
H.06.07 | | Oxytetracycline (oral) | Trimethoprim (oral)
J.01.02 | | Oxytetracycline (oral)/vitamin A (topical) | Oxytetracycline (oral)
H.09.02 | | Phenethicillin (oral) | Placebo (oral)
H.09.03 | H.02.02 | Phenethicillin (oral) | Demethylchlortetracycline (oral)
A.01.03 | E.05.01 | Polyprepolymer-2 (topical) | Tretinoin (topical)
B.05.01 | | Polythionate/quaternary ammonia complex of | Polythionate (topical)
A.01.04 | | Povidone-iodine (topical) | Vehicle (topical)
M.04.10 | | Quinestradol (oral) | Placebo (oral)
N.06.03 | | Relaxation training/erythromycin/benzoyl | Erythromycin/benzoyl peroxide (topical)
E.04.01 | | Retinyl beta-glucuronide (topical) | Vehicle (topical)
E.04.02 | | Retinyl beta-glucuronide (topical) | Tretinoin (topical)
H.04.05 | | Roxithromycin (150 mg) (oral) | Roxithromycin (300 mg) (oral)
B.03.01 | | Salicylic acid (topical) | Placebo (topical)
B.03.02 | D.01.04 | Salicylic acid (topical) | Benzoyl peroxide (topical)
M.04.11 | | Serum gonadotrophin (oral) | Placebo (oral)
A.01.05 | | Silicic acid (topical) | Vehicle (topical)
H.09.04 | | Sodium fusidate (oral) | Sodium fusidate (topical)
M.03.01 | | Spironolactone (oral) | Placebo (oral)
N.03.03 | | Staphylococcal toxoid (topical) | Vehicle (topical)
H.07.02 | | Sulfadimethoxine (oral) | Placebo (oral)
B.04.01 | D.01.05 | Sulphur/resorcinol (topical) | Benzoyl peroxide (topical)
B.04.02 | E.06.02 | Sulphur/resorcinol (topical) | Vitamin A (topical)
B.05.02 | | Sulphurated lime (topical) | Vehicle (topical)
N.01.05 | | Tea tree oil (topical) | Benzoyl peroxide (topical)
H.08.01 | | Tetracycline (oral) | Placebo (oral)
H.08.02 | | Tetracycline (oral) | Clindamycin (topical)
H.08.03 | | Tetracycline (oral) | Erythromycin (topical)
H.08.04 | | Tetracycline (oral) | Tetracycline (topical)
H.08.05 | | Tetracycline (oral) | Azelaic acid (topical)
H.08.06 | | Tetracycline (oral) | Meclocycline sulfosalicylate (topical)
H.08.07 | H.01.02 | Tetracycline (oral) | Clindamycin (oral)
H.08.08 | | Tetracycline (oral) | Tetracycline (oral)
H.08.09 | K.02.03 | Tetracycline (oral) | Isotretinoin (oral)
H.08.10 | | Tetracycline (oral) | Cyproterone/ethinyl estradiol (oral)
H.08.11 | N.01.02 | Tetracycline (oral) | Guglipid (oral)
H.08.12 | N.01.04 | Tetracycline (oral) | Ocimum basilicum (oral)
H.08.13 | N.07.03 | Tetracycline (oral) | Zinc (oral)
H.08.14 | | Tetracycline (oral)/povidone-iodine | Tetracycline (oral)
I.02.01 | | Tetracycline (oral)/sulphur/salicylic | Tretinoin/benzoyl peroxide/water avoidance
J.01.03 | | Tetracycline (oral)/tretinoin/emollient (topical) | Tetracycline (oral)/sulphur/salicylic
C.08.01 | | Tetracycline (topical) | Vehicle (topical)
C.08.02 | C.01.05 | Tetracycline (topical) | Clindamycin (topical)
C.08.03 | | Tetracycline (topical) | Benzoyl peroxide (topical)
C.08.04 | H.08.14 | Tetracycline (topical) | Povidone-iodine/tetracycline (topical)
C.08.05 | H.06.05 | Tetracycline (topical) | Oxytetracycline (oral)
C.08.06 | H.08.05 | Tetracycline (topical) | Tetracycline (oral)
H.09.05 | | Tetracycline/novobiocin (oral) | Placebo (oral)
H.08.085 | | Tetracycline/sodium novobiocin (oral) | Placebo (oral)
N.06.05 | | Tolbutamide (oral) | Placebo (oral)
E.05.01 | | Tretinoin (topical) | Vehicle (topical)
E.05.015 | | Tretinoin (topical) | Salicylic acid/resorcinol/sulphur (topical)
E.05.02 | | Tretinoin (topical) | Benzoyl peroxide (topical)
E.05.03 | E.03.03 | Tretinoin (topical) | Motretinide (topical)
E.05.04 | | Tretinoin (topical) | Azelaic acid (topical)
E.05.05 | E.02.04 | Tretinoin (topical) | Isotretinoin (topical)
E.05.06 | E.04.02 | Tretinoin (topical) | Retinyl beta-glucuronide (topical)
E.05.07 | | Tretinoin (topical) | Tretinoin (topical)
E.05.08 | | Tretinoin (topical) | Methylprednisolone/neomycin (topical)
E.05.09 | | Tretinoin (topical) | Chloramphenical/hydrocortisone (topical)
G.02.01 | | Tretinoin/clindamycin (topical) | Clindamycin (topical)
G.02.02 | | Tretinoin/clindamycin (topical) | Tretinoin (topical)
G.02.03 | | Tretinoin/clindamycin (topical) | Tetracycline (topical)
G.01.01 | | Tretinoin/erythromycin (topical) | Vehicle (topical)
C.09.01 | | Triclosan (topical) | Vehicle (topical)
C.09.02 | | Triclosan (topical) | Hexachlorophene (topical)
C.09.03 | | Triclosan/propylene phenoxetol (topical) | Vehicle (topical)
N.03.02 | | Unfractionated dialyzable transfer factor | Fractionated dialyzable transfer factor (topical)
K.03.01 | | Vitamin A (oral) | Placebo (oral)
K.03.02 | | Vitamin A (oral) | Zinc Sulfate (oral)
E.06.01 | | Vitamin A (topical) | Vehicle (topical)
E.06.02 | | Vitamin A (topical) | Keratolytics (topical)
E.06.03 | | Vitamin A (topical) | Oxytetracycline (oral)
N.07.01 | | Zinc (topical) | Vehicle (topical)
N.07.02 | | Zinc sulphate (oral) | Placebo (oral)
N.07.03 | | Zinc sulphate/citrate complex (oral) | Tetracycline (oral)
N.08.01 | | Zinc/erythromycin (topical) | Vehicle (topical)
N.08.02 | | Zinc/erythromycin (topical) | Erythromycin (topical)
N.08.03 | | Zinc/erythromycin (topical) | Clindamycin phosphate (topical)

a Index numbers for the indicated comparison. Data are found in tables labeled by the first letter of the index E.g., M.04.04 is found in Table M

b These indexes refer to the primary comparisons (Comparison Index).