# Bibliography

Adams J, Thorn P. Topical fusidic acid versus peroral doxycycline in the treatment of patients with acne vulgaris of the face. Curr Ther Res Clin Exp. 1991;50:268-273.
Adams RM, Burdick KH. An antiandrogen delta 1 chlormadinone acetate in acne: lack of effect topically. Acta Derm Venereol. 1970;50:479-80. [pmid: 4099161].
Agrawal P, Singh PK, Pandey SS, et al. Oral zinc in acne vulgaris (a double blind evaluation). Indian J Dermatol Venereol Leprol. 1985;51:38-39.
Akamatsu H, Nishijima S, Akamatsu M, et al. Clinical evaluation of roxithromycin in patients with acne. J Int Med Res. 1996;24:109-14. [pmid: 8674787].
Akers WA, Maibach HI Antibiotics and acne Int J Dermatol 1975 14(10):741 2 127752
Al Mishari MA. Clinical and bacteriological evaluation of tetracycline and erythromycin in acne vulgaris. Clin Ther. 1987;9:273-80. [pmid: 2955899].
Al Mishari MA. A study of isotretinoin (Roaccutan) in nodulocystic acne. Clin Trials J. 1986;23:1-5.
Alexander S, Vickers HR. The treatment of acne vulgaris with graded abrasive creams. Report of a clinical trial. Practitioner. 1961;186:92-4. [pmid: 13682370].
Allen BS, Smith JG Jr Various parameters for grading acne vulgaris Arch Dermatol 1982 118(1):23 5 6460474
Alster TS, McMeekin TO Improvement of facial acne scars by the 585 nm flashlamp-pumped pulsed dye laser J Am Acad Dermatol 1996 35(1):79 81 8682969
Amer M, Ramadan A, Abdel Monem A Anti-androgens in treatment of acne vulgaris Int J Dermatol 1985 24(8):533 4 2933345
Anderson R, Rajagopalan R Responsiveness of the dermatology specific quality of life (DSQL) instrument to treatment for acne vulgaris in a placebo-controlled clinical trial Qual Life Res 1998 7(8):723 34 10097621
Anderson RL, Cook CH, Smith DE. The effect of oral and topical tetracycline on acne severity and on surface lipid composition. J Invest Dermatol. 1976;66:172-7. [pmid: 129494].
Anonymous Acne vulgaris and systemic antibiotics JAMA 1966 196(4):
Anonymous Ad Hoc Committee report: systemic antibiotics for treatment of acne vulgaris: efficacy and safety Arch Dermatol 1975 111(12):1630 6 128326
Anonymous Effective medication for severe acne documented as cause of birth defects. Accutane. Occupational Health Nursing 1984 32(10):556 7
Anonymous New hope in acne [editorial] Lancet 1979 1(8128):1222 3 87684
Anonymous Over-the-counter update Community Nurse 1996 2(1 Nurse Prescriber):
Anonymous. Retinoic acid in the treatment of acne. A report from the General Practitioner Research Group. Practitioner. 1974;213:387-90. [pmid: 4278852].
Anonymous Self esteem: acne continues to assault the confidence of America's teens School Nurse News 1995 12(1):
Anonymous Skin diseases lower self perception, study finds Journal of Practical Nursing 1996 46(4):27 8
Anonymous Topicycline--a topical tetracycline for acne Med Lett Drugs Ther 1978 20(7):35 6 147383
Anonymous. Vitamin A in acne vulgaris: report by the South-East Scotland Faculty of the College of General Practitioners. Br Med J. 1963;2:294-6. [pmid: 20789943].
Ashorn R, Uotila A, Kuokkanen K, et al. Cellular immunity in acne vulgaris during transfer factor treatment. Ann Clin Res. 1985;17:152-5. [pmid: 2934019].
Ashurst PJ Tetracycline in acne vulgaris Practitioner 1968 200(198):539 41 4232398
Ashurst PJ. The treatment of acne. A comparison of 'quinoderm' and 'quinoderm hydrocortisone' creams. Practitioner. 1964;193:192-4. [pmid: 14199634].
Aydinlik S, Lachnit-Fixson U, Lehnert J Reduced estrogen ovulation inhibitor in acne therapy. Double-blind study comparing Diane-35 to Diane Fortschr Med 1986 104(27-28):547 50 2943651
Bacon P Nutrition and skin care Community Nurse 1995 1(7):
Balambal R, Thiruvengadam KV, Kameswarant L, et al. Ocimum basilicum in acne vulgaris--a controlled comparison with a standard regime. J Assoc Physicians of India. 1985;33:507-8. [pmid: 2932427].
Bassett IB, Pannowitz DL, Barnetson RS. A comparative study of tea-tree oil versus benzoyl peroxide in the treatment of acne. Med J Aust. 1990;153:455-8. [pmid: 2145499].
Baumal A, Kantor I. Acne treated with bithionol lotion. Skin. 1963;2:165-7. [pmid: 13966980].
Becker FT, Bronstein SB, Jacobson C, et al. Clinical evaluation of 16-epiestriol-3-allyl ether in acne vulgaris. A collaborative study. Arch Dermatol. 1965;91:155-8. [pmid: 14237600].
Becker LE, Bergstresser PR, Whiting DA, et al. Topical clindamycin therapy for acne vulgaris. A cooperative clinical study. Arch Dermatol. 1981;117:482-5. [pmid: 6455095].
Bergfeld WF The evaluation and management of acne: economic considerations J Am Acad Dermatol 1995 32(5 Pt 3):S52 6 7738228
Bergfeld WF Retinoids and hair growth J Am Acad Dermatol 1998 39(2 Pt 3):S86 9 9703131
Bettley FR, Dale TL. The local treatment of acne. Br J Clin Pract. 1976;30:67-9. [pmid: 130922].
Bikowski J Effectively treating acne vulgaris Physician & Sportsmedicine 1992 20(8):100 2
Bladon PT, Burke BM, Cunliffe WJ, et al. Topical azelaic acid and the treatment of acne: a clinical and laboratory comparison with oral tetracycline. Br J Dermatol. 1986;114:493-9. [pmid: 2938615].
Blaney DJ, Cook CH. Topical use of tetracycline in the treatment of acne: a double-blind study comparing topical and oral tetracycline therapy and placebo. Arch Dermatol. 1976;112:971-3. [pmid: 132901].
Blau S, Kanof NB. Polyoxyethelene lauryl ether. Its use in a new keratolytic acne lotion. AMA Arch Derm. 1960;82:266-7. [pmid: 13801400].
Bleeker J. Tolerance and efficacy of erythromycin stearate tablets versus enteric-coated erythromycin base capsules in the treatment of patients with acne vulgaris. J Int Med Res. 1983;11:38-41. [pmid: 6219902].
Bleeker J, Hellgren L, Vincent J. Effect of systemic erythromycin stearate on the inflammatory lesions and skin surface fatty acids in acne vulgaris. Dermatologica. 1981;162:342-9. [pmid: 6454598].
Blinstrub RS, Lehman R, Sternberg TH, et al. A comparison of oral and intramuscular triamcinolone in the treatment of acne vulgaris. Curr Ther Res Clin Exp. 1963;19:415-21.
Bluefarb SM, Schmitt CL, Howell CM Jr. Topical drying agents for acne. JAMA. 1960;173:40-1.
Bodokh I, Jacomet Y, Lacour JP, et al. Minocycline induces an increase in the number of excreting pilosebaceous follicles in acne vulgaris. A randomised study. Acta Derm Venereol. 1997;77:255-9. [pmid: 9228213].
Bojar RA, Eady EA, Jones CE, et al. Inhibition of erythromycin-resistant propionibacteria on the skin of acne patients by topical erythromycin with and without zinc. Br J Dermatol. 1994;130:329-36. [pmid: 8148274].
Borglund E, Hagermark O, Nord CE Impact of topical clindamycin and systemic tetracycline on the skin and colon microflora in patients with acne vulgaris Scand J Infect Dis Suppl 1984 43(Suppl.):76 81 6242074
Borglund E, Kristensen B, Larsson-Stymne B, et al. Topical meclocycline sulfosalicylate, benzoyl peroxide, and a combination of the two in the treatment of acne vulgaris. Acta Derm Venereol. 1991;71:175-8. [pmid: 1675534].
Bottomley WW, Yip J, Knaggs H, et al Treatment of closed comedones-comparisons of fulguration with topical tretinoin and electrocautery with fulguration Dermatology 1993 186(4):253 7 8513189
Boudou P, Soliman H, Chivot M, et al Effect of oral isotretinoin treatment on skin androgen receptor levels in male acneic patients J Clin Endocrinol Metab 1995 80(4):1158 61 7714084
Bourne MS Comparison of two lotions for acne vulgaris Practitioner 1979 223(1334):274 6 159439
Braathen LR Topical clindamycin versus oral tetracycline and placebo in acne vulgaris Scand J Infect Dis Suppl 1984 43(Suppl.):71 5 6242073
Bradford LG, Montes LF. Topical application of vitamin A acid in acne vulgaris. South Med J. 1974;67:683-7. [pmid: 4275274].
Brandt H, Attila P, Ahokas T, et al. Erythromycin acistrate - An alternative oral treatment for acne. J Dermatol Treat. 1994;5:3-5.
Brookes DB, Moffitt RM, Sheil LP, et al. Comparison of Tretinoin and a composite formulation in the treatment of acne. Br J Clin Pract. 1978;32:349-52. [pmid: 153763].
Brown BW. Treatment of acne vulgaris by biofeedback-assisted cue-controlled relaxation and guided cognitive imagery. Dissertation Abstracts International. 1981;42.
Brown EW Acne: it isn't just for kids anymore Medical Update 1995 18(11):
Brown SK, Shalita AR Acne vulgaris Lancet 1998 351(9119):1871 6 9652685
Bruno NP, Beacham BE, Burnett JW Adverse effects of isotretinoin therapy Cutis 1984 33(5):484 6, 489 6236956
Bucknall JH, Murdoch PN. Comparison of tretinoin solution and benzoyl peroxide lotion in the treatment of acne vulgaris. Curr Med Res Opin. 1977;5:266-8. [pmid: 162728].
Burke B, Eady EA, Cunliffe WJ Benzoyl peroxide versus topical erythromycin in the treatment of acne vulgaris Br J Dermatol 1983 108(2):199 204 6218815
Burke BM, Cunliffe WJ The assessment of acne vulgaris--the Leeds technique Br J Dermatol 1984 111(1):83 92
Burton J. A placebo-controlled study to evaluate the efficacy of topical tetracycline and oral tetracycline in the treatment of mild to moderate acne. Dermatology Research Group. J Int Med Res. 1990;18:94-103. [pmid: 2140332].
Byrne BM, Costello M, Greene E Isotretinoin therapy and depression: Evidence for an association Irish Journal of Psychological Medicine 1998 15(2):58 60
Cahn MM, Levy EJ. The use of sulfadimethoxine (madribon) in the treatment of papulopustular and cystic acne vulgaris. Ann NY Acad Sci. 1959;82:84-91. [pmid: 13806806].
Cambazard F Clinical efficacy of Velac, a new tretinoin and clindamycin phosphate gel in acne vulgaris J Eur Acad Dermatol Venereol 1998 11Suppl 1:S20 7;discussion S28-9 9891905
Campbell JP, Grekin RC, Ellis CN, et al Retinoid therapy is associated with excess granulation tissue responses J Am Acad Dermatol 1983 9(5):708 13 6227639
Carlborg L Cyproterone acetate versus levonorgestrel combined with ethinyl estradiol in the treatment of acne. Results of a multicenter study Acta Obstet Gynecol Scand 1986Suppl 134:29 32
Caron D, Sorba V, Clucas A, et al. Skin tolerance of adapalene 0.1% gel in combination with other topical antiacne treatments. J Am Acad Dermatol. 1997;36:S113-5. [pmid: 9204088].
Caron D, Sorba V, Kerrouche N, et al. Split-face comparison of adapalene 0.1% gel and tretinoin 0.025% gel in acne patients. J Am Acad Dermatol. 1997;36:S110-2. [pmid: 9204087].
Cavicchini S, Caputo R. Long-term treatment of acne with 20% azelaic acid cream. Acta Derm Venereol Suppl (Stockh). 1989;143:40-4. [pmid: 2528258].
Chalker DK, Lesher JL Jr, Smith JG Jr, et al. Efficacy of topical isotretinoin 0.05% gel in acne vulgaris: results of a multicenter, double-blind investigation. J Am Acad Dermatol. 1987;17:251-4. [pmid: 2957398].
Chalker DK, Shalita A, Smith JG Jr, et al A double-blind study of the effectiveness of a 3% erythromycin and 5% benzoyl peroxide combination in the treatment of acne vulgaris J Am Acad Dermatol 1983 9(6):933 6 6227643
Chalker DK, Smith JS Jr Editorial: Systemic antibiotics and acne JAMA 1975 234(10):
Charoenvisal C, Thaipisuttikul Y, Pinjaroen S, et al. Effects on acne of two oral contraceptives containing desogestrel and cyproterone acetate. Int J Fertil Menopausal Stud. 1996;41:423-9. [pmid: 8894800].
Christian GL, Krueger GG. Clindamycin vs placebo as adjunctive therapy in moderately severe acne. Arch Dermatol. 1975;111:997-1000. [pmid: 134670].
Christiansen J, Gadborg E, Hattel T, et al. The retinoic acid derivative Ro 11-1430 (Tasmaderm) in patients with acne vulgaris not tolerating retinoic acid. A controlled multicenter trial against placebo. Dermatologica. 1979;159:466-70. [pmid: 159841].
Christiansen J, Holm P, Reymann F. The retinoic acid derivative Ro 11-1430 in Acne vulgaris. A controlled multicenter trial against retinoic acid. Dermatologica. 1977;154:219-27. [pmid: 140824].
Christiansen J, Holm P, Reymann F. Treatment of acne vulgaris with the retinoic acid derivative Ro 11-1430. A controlled clinical trial against retinoic acid. Dermatologica. 1976;153:172-6. [pmid: 138608].
Christiansen JV, Gadborg E, Ludvigsen K, et al. Topical vitamin A acid (Airol) and systemic oxytetracycline in the treatment of acne vulgaris. A controlled clinical trial. Dermatologica. 1974;149:121-8. [pmid: 4281394].
Christiansen JV, Gadborg E, Ludvigsen K, et al. Topical tretinoin, vitamin A acid (Airol) in acne vulgaris. A controlled clinical trial. Dermatologica. 1974;148:82-9. [pmid: 4276190].
Chu A, Huber FJ, Plott RT. The comparative efficacy of benzoyl peroxide 5%/erythromycin 3% gel and erythromycin 4%/zinc 1.2% solution in the treatment of acne vulgaris. Br J Dermatol. 1997;136:235-8. [pmid: 9068739].
Clucas A, Verschoore M, Sorba V, et al. Adapalene 0.1% gel is better tolerated than tretinoin 0.025% gel in acne patients. J Am Acad Dermatol. 1997;36:S116-8. [pmid: 9204089].
Coates P, Adams CA, Cunliffe WJ, et al Does oral isotretinoin prevent Propionibacterium acnes resistance? Dermatology 1997 195Suppl 1:4 9 discussion 38-40 9310739
Coates P, Eady AE, Cove JH. Complementary therapies for acne [protocol]. In: The Cochrane Libary, Issue 4, 1999. Oxford: Update Software.
Cobin IM. Treatment of cystic acne and other dermatoses with betamethasone. Clin Med. 1963;70:1316-20. [pmid: 15446015].
Cochran RJ, Tucker SB, Flannigan SA. Topical zinc therapy for acne vulgaris. Int J Dermatol. 1985;24:188-90. [pmid: 3158620].
Cohen EL. Treatment of acne vulgaris with graded abrasion. Medicina. 1962;96:101-2.
Cohen PM A general practice study investigating the effect of Minocin 50 mg b.d. for 12 weeks in the treatment of acne vulgaris J Int Med Res 1985 13(4):214 21 2931312
Colver GB, Mortimer PS, Dawber RP. Cyproterone acetate and two doses of oestrogen in female acne; a double-blind comparison. Br J Dermatol. 1988;118:95-9. [pmid: 2963663].
Condie R. Trial of ' Camyna ' in Acne Vulgaris. Practitioner. 1964;192:679-81. [pmid: 14147259].
Connolly C, Bikowsky J. Dermatology Atlas of Black Skin. Florida: Merit Publishing International; 1998.
Cook CH, Centner RL, Michaels SE An acne grading method using photographic standards Arch Dermatol 1979 115(5):571 5 156006
Cooley S, Atkinson P, Parks D, et al Practice guidelines. Management of acne vulgaris Journal of Pediatric Health Care 1998 12(1):38 40 9515498
Cooper CD, Gant JQ Jr. Treatment of acne vulgaris with esidrix-KCl. Preliminary report. Med Ann DC. 1960;29.
Corlin R, Maas B, Mack HA. Oral administration of low doses of 13-cis-retinoic acid in acne papulopustulosa. Results of a multicenter study. Hautarzt. 1984;35:623-629. [pmid: 6241188].
Cormia FE. Cyclic estrogenic and chlorothiazide therapy in acne vulgaris. AMA Arch Derm. 1960;82:821-3. [pmid: 13695540].
Cornbleet T. Comparison of demethychlortetracycline and tetracycline in acne. Arch Dermatol. 1964;89:144-6. [pmid: 14070828].
Cornbleet T. Long-term therapy of acne with tetracycline. Arch Dermatol. 1961;83:414-6. [pmid: 13695560].
Cotterill JA. Benzoyl peroxide. Acta Derm Venereol Suppl (Stockh). 1980;89:57-63. [pmid: 6162349].
Cotterill JA, Cunliffe WJ Suicide in dermatological patients Br J Dermatol 1997 137(2):246 50 9292074
Cromwell HA. Clinical evaluation of sulfalene (2-Sulfanilamido-3-Methoxypyrazine). Curr Ther Res Clin Exp. 1965;32:461-4. [pmid: 14331674].
Crounse RG. The response of acne to placebos and antibiotics. JAMA. 1965;193:906-10. [pmid: 14341135].
Cullen SI, Cohan RH. Minocycline therapy in acne vulgaris. Cutis. 1976;17:1208-10, 1214. [pmid: 138560].
Cunliffe WJ Acne and unemployment [letter] Br J Dermatol 1986 115(3):
Cunliffe WJ Acne vulgaris Nurs Times 1970 66(28):872 4 4246710
Cunliffe WJ, Burke B, Dodman B. Chloramphenicol and benzoyl peroxide in acne. A double-blind clinical study. Practitioner. 1980;224:952-4. [pmid: 6449698].
Cunliffe WJ, Burke B, Dodman B, et al. A double-blind trial of a zinc sulphate/citrate complex and tetracycline in the treatment of acne vulgaris. Br J Dermatol. 1979;101:321-5. [pmid: 159714].
Cunliffe WJ, Cotterill JA. Clindamycin as an alternative to tetracycline in severe acne vulgaris. Practitioner. 1973;210:698-700. [pmid: 4270841].
Cunliffe WJ, Dodman B, Ead R Benzoyl peroxide in acne Practitioner 1978 220(1317):479 82 148043
Cunliffe WJ, Gray JA, MacDonald-Hull S, et al. Cost effectiveness of isotretinoin. J Dermatol Treat. 1991;1:258-8.
Cunliffe WJ, Holland KT. Clinical and laboratory studies on treatment with 20% azelaic acid cream for acne. Acta Derm Venereol Suppl (Stockh). 1989;143:31-4. [pmid: 2528256].
Cunliffe WJ, Holland KT. The effect of benzoyl peroxide on acne. Acta Derm Venereol. 1981;61:267-9. [pmid: 6167116].
Cunliffe WJ, MacDonald-Hull S Lack of effect of topical retinoic acid on sebum excretion rate in acne [letter] Lancet 1988 2(8609):
Cunliffe WJ, Poncet M, Loesche C, et al A comparison of the efficacy and tolerability of adapalene 0.1% gel versus tretinoin 0.025% gel in patients with acne vulgaris: a meta- analysis of five randomized trials Br J Dermatol 1998 139Suppl 52:48 56 9990421
Cunliffe WJ, van de Kerkhof PC, Caputo R, et al Roaccutane treatment guidelines: results of an international survey Dermatology 1997 194(4):351 7 9252756
Cunliffe W, Caputo R, Dreno B, et al. Clinical efficacy and safety comparison of adapalene gel and tretinoin gel in the treatment of acne vulgaris: Europe and U.S. multicenter trials. J Am Acad Dermatol. 1997;36:S126-34. [pmid: 9204091].
Cunliffe WJ, Grosshans E, Belaich S, et al. A comparison of the efficacy and safety of lymecycline and minocycline in patients with moderately severe acne vulgaris. Eur J Dermatol. 1998;8:161-6. [pmid: 9649660].
Czernielewski A, Skwarczynska-Banys E. Oral treatment of acne vulgaris and oil acne with tetracycline. Dermatologica. 1982;165:62-5. [pmid: 6214437].
Daehnert JR. Acne and personality: A Rorschach study. Dissertation Abstracts International. 1985;46.
Danto JL, Maddin WS, Stewart WD, et al. A controlled trial of benzoyl peroxide and precipitated sulfur cream in acne vulgaris. Appl Ther. 1966;8:624-5. [pmid: 4223595].
De Bersaques J Topical vitamin A acid. Review of the literature and results of a clinical trial in acne Arch Belg Dermatol Syphiligr 1972 28(4):315 34 4274476
Degreef H, Vanden BG. Double-blind evaluation of miconazole-benzoyl peroxide combination for the topical treatment of acne vulgaris. Dermatologica. 1982;164:201-208. [pmid: 6211379].
Delaney J, Ferrara RJ, Robarge I. Treatment of acne vulgaris with polythionates incorporated in a vanishing cream. J Mich Med Soc. 1959;58:1259-61. [pmid: 13815561].
Dieben TO, Vromans L, Theeuwes A, et al. The effects of CTR-24, a biphasic oral contraceptive combination, compared to Diane-35 in women with acne. Contraception. 1994;50:373-82. [pmid: 7813225].
Divers LS. A new preparation for the topical treatment of acne vulgaris. Report of a year's study. J Coll Gen Pract. 1966;12:239-41. [pmid: 4380436].
Dobson RL, Belknap BS Topical erythromycin solution in acne. Results of a multiclinic trial J Am Acad Dermatol 1980 3(5):478 82 6452463
Dominguez J, Hojyo MT, Celayo JL, et al Topical isotretinoin vs. topical retinoic acid in the treatment of acne vulgaris Int J Dermatol 1998 37(1):54 5 9522243
Doshi A, Zaheer A, Stiller MJ A comparison of current acne grading systems and proposal of a novel system Int J Dermatol 1997 36(6):416 8 9248884
Draelow ZK Patient compliance: enhancing clinician abilities and strategies J Am Acad Dermatol 1995 32(Suppl):S42 8 7738226
Drake LA Guidelines of care for acne vulgaris J Am Acad Dermatol 1990 22(4):676 680 2138639
Dreno B, Amblard P, Agache P, et al. Low doses of zinc gluconate for inflammatory acne. Acta Derm Venereol. 1989;69:541-3. [pmid: 2575335].
Drutman H Differential contributions of field-dependence/independence, attitudes about acne, and severity of acne, to the self-concept of adolescents with acne Dissertation Abstracts International 1986 Mar 46(9-B):
Dunlap FE, Baker MD, Plott RT, et al. Adapalene 0.1% gel has low skin irritation potential even when applied immediately after washing. Br J Dermatol. 1998;139 Suppl 52:23-5.
Dunlap FE, Mills OH, Tuley MR, et al. Adapalene 0.1% gel for the treatment of acne vulgaris: its superiority compared to tretinoin 0.025% cream in skin tolerance and patient preference. Br J Dermatol. 1998;139 Suppl 52:17-22.
Dunlop KJ, Barnetson RS. A comparative study of isolutrol versus benzoyl peroxide in the treatment of acne. Australas J Dermatol. 1995;36:13-5. [pmid: 7763215].
Eady EA, Bojar RA, Jones CE, et al. The effects of acne treatment with a combination of benzoyl peroxide and erythromycin on skin carriage of erythromycin-resistant propionibacteria. Br J Dermatol. 1996;134:107-13. [pmid: 8745894].
Eady EA, Burke BM, Pulling K, et al. The benefit of 2% salicylic acid lotion in acne - A placebo-controlled study. J Dermatol Treat. 1996;7:93-96.
Eady EA, Cove JH, Joanes DN, et al. Topical antibiotics for the treatment of acne vulgaris: a critical evaluation of the literature on their clinical benefit and comparative efficacy. J Dermatol Treat. 1990;1:215-26.
Ede M. A double-blind, comparative study of benzoyl peroxide, benzoyl peroxide-chlorhydroxyquinoline, benzoyl peroxide-chlorhydroxyquinoline-hydrocortisone, and placebo lotions in acne. Curr Ther Res Clin Exp. 1973;15:624-9. [pmid: 4270828].
Edelstein AJ. Effect of triacetyloleandomycin in treatment of infected acne. Penn Med J. 1962;65:188-90. [pmid: 13889160].
Edelstein AJ. Premenstrual acne; a new therapeutic approach. Penn Med J. 1960;63:1503-4. [pmid: 13725673].
Elbaum DJ. Comparison of the stability of topical isotretinoin and topical tretinoin and their efficacy in acne. J Am Acad Dermatol. 1988;19:486-91. [pmid: 2971693].
Eller JJ. Dermal abrasion of deeply pitted acne scars. Skin. 1963;123:346-7. [pmid: 14084473].
Ellis CN, Gammon WR, Stone DZ, et al. A comparison of Cleocin T Solution, Cleocin T Gel, and placebo in the treatment of acne vulgaris. Cutis. 1988;42:245-7. [pmid: 2971512].
Ellis CN, Millikan LE, Smith EB, et al. Comparison of adapalene 0.1% solution and tretinoin 0.025% gel in the topical treatment of acne vulgaris. Br J Dermatol. 1998;139 Suppl 52:41-7. [pmid: 9990420].
Elstein W. Topical deodorized polysulfides. Broadscope acne therapy. Cutis. 1981;28:468-72. [pmid: 6458456].
Ereaux LP. A new lotion for the treatment of acne vulgaris. Can Med Assoc J. 1965;92:157-9. [pmid: 14232189].
Erkkola R, Hirvonen E, Luikku J, et al. Ovulation inhibitors containing cyproterone acetate or desogestrel in the treatment of hyperandrogenic symptoms. Acta Obstet Gynecol Scand. 1990;69:61-5. [pmid: 2140663].
Esterly NB, Koransky JS, Furey NL, et al Neutrophil chemotaxis in patients with acne receiving oral tetracycline therapy Arch Dermatol 1984 120(10):1308 13 6237616
Exner JH, Dahod S, Pochi PE Pyogenic granuloma-like acne lesions during isotretinoin therapy Arch Dermatol 1983 119(10):808 11 6225396
Facklam DP, Gardner JS, Neidert GL, et al An epidemiologic postmarketing surveillance study of prescription acne medications Am J Public Health 1990 80(1):50 3 2136713 1404540
Fanta D. Cyproterone acetate in acne. J Dermatol Treat. 1990;1:S19-S22.
Fanta D, Scholz N Miconazole-benzoyl peroxide: A new combination to extend the topical therapy of acne Z Hautkr 1984 59(13):873 881 6235682
Farrell LN, Strauss JS, Stranieri AM The treatment of severe cystic acne with 13-cis-retinoic acid. Evaluation of sebum production and the clinical response in a multiple dose trial J Am Acad Dermatol 1980 3(6):602 11 6451637
Fatum B, Hansen HHV, Mortensen E. Topical treatment of acne vulgaris with the vitamin A acid derivate motretinide (Tasmaderm(Reg.trademark)), tretinoin (Airol (Reg.trademark)) and a placebo cream. Ugeskr Laeg. 1980;142:3364-3366.
Feucht CL, Allen BS, Chalker DK, et al Topical erythromycin with zinc in acne. A double-blind controlled study J Am Acad Dermatol 1980 3(5):483 91 6452464
Fitzpatrick SB, Fujii C, Shragg GP, et al Do health care needs of indigent Mexican-American, Black, and White adolescents differ? J Adolesc Health Care 1990 11(2):128 132 2318711
Flanders PA, McNamara JR Enhancing acne medication compliance: a comparison of strategies Behav Res Ther 1985 23(2):225 7 3159380
Flanders PA, McNamara JR Prediction of compliance with an over-the-counter acne medication J Psychol 1984 118(1):31 36 6239919
Flinn JH. The treatment of acne with tolbutamide. Student Med. 1961;9:234-7.
Fluckiger R, Furrer HJ, Rufli T. Efficacy and tolerance of a miconazole-benzoyl peroxide cream combination versus a benzoyl peroxide gel in the topical treatment of acne vulgaris. Dermatologica. 1988;177:109-14. [pmid: 2971582].
Fluhr JW, Gloor M, Merkel W, et al Antibacterial and sebosuppressive efficacy of a combination of chloramphenicol and pale sulfonated shale oil. Multicentre, randomized, vehicle-controlled, double-blind study on 91 acne patients with acne papulopustulosa (Plewig and Kligman's grade II-III) Arzneimittelforschung 1998 48(2):188 96 9541732
Frank L, Stritzler C. Long-term therapy of acne with antibiotics. N Y J Med. 1959;59:3237-9.
Frank SB Topical treatment of acne with a tetracycline preparations: results of a multi-group study Cutis 1976 17(3):539 45 138548
Franz E, Weidner-Strahl S. The effectiveness of topical antibacterials in acne: a double-blind clinical study. J Int Med Res. 1978;6:72-7. [pmid: 146628].
Fraser NB, Main RA, Stewart TW, et al. Treatment of acne vulgaris comparing two similar lotion formulations, one with ('Actinac') and one without chloramphenicol. Curr Med Res Opin. 1980;6:461-5. [pmid: 6444862].
Freinkel RK, Lurie AS. Some observations on the effect of 1-tri-iodothyronine on acne vulgaris. J Invest Dermatol. 1960;34:277-9. [pmid: 13824820].
Fugere P, Percival-Smith RK, Lussier-Cacan S, et al. Cyproterone acetate/ethinyl estradiol in the treatment of acne. A comparative dose-response study of the estrogen component. Contraception. 1990;42:225-34. [pmid: 2150795].
Fyrand O, Jakobsen HB. Water-based versus alcohol-based benzoyl peroxide preparations in the treatment of acne vulgaris. Dermatologica. 1986;172:263-7. [pmid: 2943613].
Galen BA Protocols. Acne vulgaris Lippincotts Prim Care Pract 1997 1(1):88 92 9166612
Galvin SA, Gilbert R, Baker M, et al Comparative tolerance of adapalene 0.1% gel and six different tretinoin formulations Br J Dermatol 1998 139Suppl 52:34 40 9990419
Gamborg-Nielsen P. Topical metronidazole gel. Use in acne vulgaris. Int J Dermatol. 1991;30:662-6. [pmid: 1834598].
Gammon WR, Meyer C, Lantis S, et al. Comparative efficacy of oral erythromycin versus oral tetracycline in the treatment of acne vulgaris. A double-blind study. J Am Acad Dermatol. 1986;14:183-6. [pmid: 2936772].
Gandola M, Argenziano G, Barba C, et al. Topical vitamin A acid in the treatment of acne vulgaris (a controlled multicenter trial). Arch Dermatol Res. 1976;255:129-38. [pmid: 132142].
Ganpule M Clomocycline and oxytetracycline in acne vulgaris Practitioner 1968 201(203):479 82 4234717
Garner SE, Eady EA, Li Wan Po A, et al. Minocycline for acne [protocol]. In: The Cochrane Library, Issue 1, 1999. Oxford: Update Software.
Garrie SA, Garrie EV Anxiety and skin diseases Cutis 1978 22(2):205 8 150966
Gaul LE. Salt restriction in acne vulgaris. J Indiana State Med Assoc. 1965;58:839-42. [pmid: 14321443].
Geiger JM, Hommel L, Harms M, et al. Oral 13-cis retinoic acid is superior to 9-cis retinoic acid in sebosuppression in human beings. J Am Acad Dermatol. 1996;34:513-5. [pmid: 8609271].
Geist H. Emotional aspects of dermatitis. Journal of Clinical and Experimental Psychopathology. 1957;18:87-93.
Gibson JR Azelaic acid 20% cream (AZELEX) and the medical management of acne vulgaris Dermatol Nurs 1997 9(5):339 44 9392765
Gibson JR, Darley CR, Harvey SG, et al. Oral trimethoprim versus oxytetracycline in the treatment of inflammatory acne vulgaris. Br J Dermatol. 1982;107:221-224. [pmid: 6213255].
Gibson JR, Harvey SG, Barth J, et al Assessing inflammatory acne vulgaris--correlation between clinical and photographic methods Br J Dermatol 1984 111Suppl 27:168 70 6234920
Gidwani GP Norgestimate and ethinyl estradiol in the treatment of acne vulgaris: a randomized, placebo-controlled trial Clin Pediatr (Phila) 1998 37(1):358331
Girman CJ, Hartmaier S, Thiboutot D, et al Evaluating health-related quality of life in patients with facial acne: development of a self-administered questionnaire for clinical trials Qual Life Res 1996 5(5):481 90 8973127
Goldstein JA, Socha-Szott A, Thomsen RJ, et al Comparative effect of isotretinoin and etretinate on acne and sebaceous gland secretion J Am Acad Dermatol 1982 6(4 Pt 2 Suppl):760 5 6461679
Goltz RW, Coryell GM, Schnieders JR, et al. A comparison of Cleocin T 1 percent solution and Cleocin T 1 percent lotion in the treatment of acne vulgaris. Cutis. 1985;36:265-8. [pmid: 2932307].
Goodfellow A, Alaghband-Zadeh J, Carter G, et al. Oral spironolactone improves acne vulgaris and reduces sebum excretion. Br J Dermatol. 1984;111:209-214. [pmid: 6235834].
Goransson K, Liden S, Odsell L. Oral zinc in acne vulgaris: a clinical and methodological study. Acta Derm Venereol. 1978;58:443-8. [pmid: 82356].
Goth A, Nebenfuehrer L. Treatment of acne and menstrual disorders with small doses of predisolone. J Clin Endocrinol Metab. 1964;24.
Gould AH, Weingarten MF. The treatment of acne vulgaris with a thyroid hormone substance-liothyronine. Med Ann DC. 1959;28:556-8. [pmid: 13828569].
Gould DJ, Ead R, Cunliffe WJ Oral tetracycline and retinoic acid gel in acne Practitioner 1978 221(1322):268 71 152913
Goulden V, Clark SM, McGeown C, et al Treatment of acne with intermittent isotretinoin Br J Dermatol 1997 137(1):106 8 9274635
Goulden V, Glass D, Cunliffe WJ. Safety of long-term high-dose minocycline in the treatment of acne. Br J Dermatol. 1996;134:693-5. [pmid: 8733373].
Goulden V, Layton AM, Cunliffe WJ Current indications for isotretinoin as a treatment for acne vulgaris Dermatology 1995 190(4):284 7 7655106
Goulden V, Layton AM, Cunliffe WJ Long-term safety of isotretinoin as a treatment for acne vulgaris Br J Dermatol 1994 131(3):360 3 7918010
Gratton D, Raymond GP, Guertin-Larochelle S, et al Topical clindamycin versus systemic tetracycline in the treatment of acne. Results of a multiclinic trial J Am Acad Dermatol 1982 7(1):50 3 6213682
Greenwood R, Brummitt L, Burke B, et al. Acne: double blind clinical and laboratory trial of tetracycline, oestrogen-cyproterone acetate, and combined treatment. Br Med J Clin Res Ed. 1985;291:1231-5.
Groot WP de, Prakken J, Verbeek A, et al. The value of grenz-ray therapy for acne vulgaris. Dermatologica. 1963;126:319-25. [pmid: 13950714].
Grosshans E, Marks R, Mascaro JM, et al Evaluation of clinical efficacy and safety of adapalene 0.1% gel versus tretinoin 0.025% gel in the treatment of acne vulgaris, with particular reference to the onset of action and impact on quality of life Br J Dermatol 1998 139Suppl 52:26 33 9990418
Grover RW, Arikian N. The effect of intralesional insulin and glucagon in acne vulgaris. J Invest Dermatol. 1963;40:259-61. [pmid: 13950866].
Gruber DM, Sator MO, Joura EA, et al Topical cyproterone acetate treatment in women with acne: a placebo-controlled trial Arch Dermatol 1998 134(4):459 63 9554298
Guerrier CJ, Thornton EJ. Double-blind comparison of two similar lotion formulations, one without and the other with hydrocortisone acetate ('Actinac') in the treatment of acne vulgaris. Curr Med Res Opin. 1980;6:377-9. [pmid: 6444861].
Guin JD. Topical clindamycin: a double-blind study comparing clindamycin phosphate with clindamycin hydrochloride. Int J Dermatol. 1979;18:164-6. [pmid: 154479].
Guin JD Treatment of acne vulgaris with topical clindamycin phosphate: a double-blind study Int J Dermatol 1981 20(4):286 8 6453849
Gunning DB, Barua AB, Lloyd RA, et al. Retinoyl beta-glucuronide: A nontoxic retinoid for the topical treatment of acne. J Dermatol Treat. 1994;5:181-185.
Gupta MA, Gupta AK, Schork NJ, et al Psychiatric aspects of the treatment of mild to moderate facial acne. Some preliminary observations Int J Dermatol 1990 29(10):719 21 2148562
Habbema L, Koopmans B, Menke HE, et al. A 4% erythromycin and zinc combination (Zineryt) versus 2% erythromycin (Eryderm) in acne vulgaris: a randomized, double-blind comparative study. Br J Dermatol. 1989;121:497-502. [pmid: 2533878].
Handojo I. The aromatic ethylamide derivative of retinoic acid in the treatment of acne vulgaris. Southeast Asian J Trop Med Public Health. 1977;8:311-6. [pmid: 146916].
Handojo I The combined use of topical benzoyl peroxide and tretinoin in the treatment of acne vulgaris Int J Dermatol 1979 18(6):489 96 158570
Handojo I. Retinoic acid cream (Airol cream) and benzoyl-peroxide in the treatment of acne vulgaris. Southeast Asian J Trop Med Public Health. 1979;10:548-51. [pmid: 161417].
Hanfling SL. Oral therapy of pustular acne with sulfadimethoxine. Med Times. 1962;90:166-72. [pmid: 13904332].
Hansted B, Jorgensen J, Reymann F, et al. Fucidin(Reg.trademark) cream for topical treatment of acne vulgaris. Curr Ther Res. 1985;37:249-253.
Harcup JW, Cooper J. The treatment of acne vulgaris in general practice. A double-blind assessment of co-trimoxazole and tetracycline. Practitioner. 1980;224:747-50. [pmid: 6448998].
Hare PJ. Benzoyl peroxide gel compared with retinoic acid in acne vulgaris. Br J Clin Pract. 1975;29:63-6. [pmid: 124185].
Harms M, Philippe I, Radeff B, et al. Arotinoid Ro 13-6298 and etretin: two new retinoids inferior to isotretinoin in sebum suppression and acne treatment. Acta Derm Venereol. 1986;66:149-54. [pmid: 2424239].
Harrison PV A comparison of doxycycline and minocycline in the treatment of acne vulgaris Clin Exp Dermatol 1988 13(4):242 4 2977578
Hatwal A, Bhatt RP, Agrawal JK, et al. Spironolactone and cimetidine in treatment of acne. Acta Derm Venereol. 1988;68:84-7. [pmid: 2449021].
Healy E, Simpson N Acne vulgaris Br Med J 1994 308(6932):831 3 8167492
Hellgren L, Vincent J Erythromycin stearate in acne vulgaris: its effect on the skin surface lipids and on the activity of purified pancreatic lipase Dermatologica 1978 156(2):105 10 145975
Hellgren L, Vincent J Topical erythromycin for acne vulgaris Dermatologica 1980 161(6):409 14 6452297
Henderson TA, Olson WH, Leach AD. A single-blind, randomized comparison of erythromycin pledgets and clindamycin lotion in the treatment of mild to moderate facial acne vulgaris. Adv Ther. 1995;12:172-177.
Hennes R, Mack A, Schell H, et al 13-cis-retinoic acid in conglobate acne. A follow-up study of 14 trial centers Arch Dermatol Res 1984 276(4):209 15 6236757
Hermes B, Praetel C, Henz BM Medium dose isotretinoin for the treatment of acne J Eur Acad Dermatol Venereol 1998 11(2):117 21 9784036
Herold WC. Sebaceous inhibition with 16-epiestriol-3-allyl ether. Preliminary report. Arch Dermatol. 1962;85:628-32.
Hersle K. Trimethoprim-sulphamethoxazole in acne vulgaris. A double-blind study. Dermatologica. 1972;145:187-91.
Hersle K, Gisslen H. Minocycline in acne vulgaris: a double-blind study. Curr Ther Res Clin Exp. 1976;19:339-42. [pmid: 131678].
Hicks JH. Demethylchloretracycline: a double-blind study in the treatment of acne with attention to side-effects noted. South Med J. 1962;55:357-60. [pmid: 13907192].
Hillstrom L, Pettersson L, Hellbe L, et al. Comparison of oral treatment with zinc sulphate and placebo in acne vulgaris. Br J Dermatol. 1977;97:679-84.
Hjorth N. Indications of vitamin A acid treatment in acne vulgaris. Acta Derm Venereol Suppl (Stockh). 1975;74:116-8. [pmid: 130773].
Hjorth N, Graupe K. Azelaic acid for the treatment of acne. A clinical comparison with oral tetracycline. Acta Derm Venereol Suppl (Stockh). 1989;143:45-8. [pmid: 2528259].
Hjorth N, Schmidt H, Thomsen K, et al. Meclosorb, a new topical antibiotic agent in the treatment of acne vulgaris: a double-blind clinical study. Acta Derm Venereol. 1984;64:354-7. [pmid: 6209900].
Hjorth N, Storm D, Dela K. Topical anhydrous aluminum chloride formulation in the treatment of acne vulgaris: a double-blind study. Cutis. 1985;35:499-500. [pmid: 3159552].
Horne SF. Sulfadimethoxine in acne and cutaneous lesions. Med Times. 1961;89:401-3. [pmid: 13715893].
Hua Z. Double blind study on tanshinone versus placebo in the treatment of acute vulgaris and the effects on sebum excretion rate and propionibacterium acnes counts. Chin Med J. 1993;106.
Hubbell CG, Hobbs ER, Rist T, et al Efficacy of minocycline compared with tetracycline in treatment of acne vulgaris Arch Dermatol 1982 118(12):989 92 6216858
Hughes BR, Cunliffe WJ. A prospective study of the effect of isotretinoin on the follicular reservoir and sustainable sebum excretion rate in patients with acne. Arch Dermatol. 1994;130:315-8. [pmid: 8129409].
Hughes BR, Norris JF, Cunliffe WJ. A double-blind evaluation of topical isotretinoin 0.05%, benzoyl peroxide gel 5% and placebo in patients with acne. Clin Exp Dermatol. 1992;17:165-8. [pmid: 1451291].
Hughes H, Brown BW, Lawlis GF, et al. Treatment of acne vulgaris by biofeedback relaxation and cognitive imagery. J Psychosom Res. 1983;27:185-91. [pmid: 6224928].
Hull SM, Cunliffe WJ. The use of a corticosteroid cream for immediate reduction in the clinical signs of acne vulgaris. Acta Derm Venereol. 1989;69:452-3. [pmid: 2572120].
Hunt MJ, Barnetson RS. A comparative study of gluconolactone versus benzoyl peroxide in the treatment of acne. Australas J Dermatol. 1992;33:131-4. [pmid: 1303072].
Hurwitz S Acne vulgaris Pediatr Ann 1976 5(12):772 81 136627
Hurwitz S Acne vulgaris. Current concepts of pathogenesis and treatment Am J Dis Child 1979 133(5):536 44 155397
Hurwitz S Acne Vulgaris: Its Pathogenesis and Management Adolesc Med 1990 1(2):301 314 10350714
Hurwitz S Acne vulgaris: pathogenesis and management Pediatr Rev 1994 15(2):47 52; quiz 53 8159625
Hurwitz S The combined effect of vitamin A acid and benzoyl peroxide in the treatment of acne Cutis 1976 17(3):585 90 138552
Jaffe GV, Grimshaw JJ, Constad D. Benzoyl peroxide in the treatment of acne vulgaris: a double-blind, multi-centre comparative study of 'Quinoderm' cream and 'Quinoderm' cream with hydrocortisone versus their base vehicle alone and a benzoyl peroxide only gel preparation. Curr Med Res Opin. 1989;11:453-62. [pmid: 2528439].
James M Isotretinoin for severe acne [see comments] Lancet 1996 347(9017):1749 50 8656912
Jansen T, Plewig G Acne fulminans Int J Dermatol 1998 37(4):254 7 9585893
Jelinek JE. Hydrochlorothiazide and the control of premenstrual exacerbation of acne. Arch Dermatol. 1972;105:79-80. [pmid: 4257912].
Jelliffe AM, Soutter C, Meara RH. An investigation into the treatment of acne vulgaris with Grenz x-rays. Br J Dermatol. 1969;81:617-20. [pmid: 4240710].
Jemec GB, Rasmussen I Bone lesions of acne fulminans. Case report and review of the literature [see comments] J Am Acad Dermatol 1989 20(2 Pt 2):353 7 2521643
Jen I A comparison of low dosage trimethoprim/sulfamethoxazole with oxytetracycline in acne vulgaris Cutis 1980 26(1):106 8 6446446
Jick SS, Terris BZ, Jick H First trimester topical tretinoin and congenital disorders [see comments] Lancet 1993 341(8854):1181 2 8098078
Johnson R, Nusbaum BP, Horwitz SN, et al Transfer of topically applied tetracycline in various vehicles Arch Dermatol 1983 119(8)660 3 6870319
Jones DH, King K, Miller AJ, et al. A dose-response study of I3-cis-retinoic acid in acne vulgaris. Br J Dermatol. 1983;108:333-43. [pmid: 6219690].
Jones EL, Crumley AF. Topical erythromycin vs blank vehicle in a multiclinic acne study. Arch Dermatol. 1981;117:551-3. [pmid: 6457568].
Jones H, Blanc D, Cunliffe WJ. 13-cis retinoic acid and acne. Lancet. 1980;2:1048-9. [pmid: 6107678].
Jones H, Simpson NB, Blanc D, et al. Lack of effect of cimetidine in acne [letter]. Lancet. 1980;2:1201-2.
Jordan RE, Cummins CL, Burls AJE, et al. Laser resufacing for facial acne scars [protocol]. In: The Cochrane Library, Issue 4, 1999. Oxford: Update Software.
Jowett S, Ryan T Skin disease and handicap: An analysis of the impact of skin conditions Soc Sci and Med 1985 20(4):425 429 3158080
Juhlin L, Liden S A quantitative evaluation of the effect of oxytetracycline and doxycycline in acne vulgaris Br J Dermatol 1969 81(2):154 8 4237366
Juhlin L, Michaelsson G, Ohman S Topical triamcinolone acetonide and chlorhydroxyquinoline in acne Acta Derm Venereol 1968 48(3):255 6 4176750
Kamm JJ Toxicology, carcinogenicity, and teratogenicity of some orally administered retinoids J Am Acad Dermatol 1982 6(4 Pt 2 Suppl):652 9 7040511
Kanigsberg N, DesGroseilliers JP Use of 13-cis-retinoic acid in cystic acne [letter] Can Med Assoc J 1983 129(3):
Kaplan EN, Falces E, Tolleth H Clinical utilization of injectable collagen Ann Plast Surg 1983 10(6):437 51 6224455
Karvonen SL Acne fulminans: report of clinical findings and treatment of twenty-four patients J Am Acad Dermatol 1993 28(4):572 9 7681856
Karvonen SL, Vaalasti A, Kautiainen H, et al Systemic corticosteroid and isotretinoin treatment in cystic acne Acta Derm Venereol 1993 73(6):452 5 7906462
Katsambas A, Graupe K, Stratigos J. Clinical studies of 20% azelaic acid cream in the treatment of acne vulgaris. Comparison with vehicle and topical tretinoin. Acta Derm Venereol Suppl (Stockh). 1989;143:35-9. [pmid: 2528257].
Katsambas A, Towarky AA, Stratigos J. Topical clindamycin phosphate compared with oral tetracycline in the treatment of acne vulgaris. Br J Dermatol. 1987;116:387-91. [pmid: 2952156].
Kern AB. Gamma-globulin in treatment of acne and psoriasis. Arch Dermatol. 1962;85:623-4. [pmid: 14455276].
Kilkenny M, Merlin K, Plunkett A, et al The prevalence of common skin conditions in australian school students: 3. Acne vulgaris Br J Dermatol 1998 139(5):840 5 9892951
King K, Jones DH, Daltrey DC, et al A double-blind study of the effects of 13-cis-retinoic acid on acne, sebum excretion rate and microbial population Br J Dermatol 1982 107(5):583 90 6215056
Kirton V. Evaluation of new preparation for the treatment of acne vulgaris. Br J Clin Pract. 1967;21:127-8. [pmid: 4227626].
Klessens NF. Clinical trial of triacetyloleandomycin in the treatment of acne conglobata, nummular dermatitis and other resistant coccogenous dermatologic infections. Antibiot Chemother. 1962;12:551-3. [pmid: 14456900].
Kligman AM The growing importance of topical retinoids in clinical dermatology: a retrospective and prospective analysis J Am Acad Dermatol 1998 39(2 Pt 3):S2 7 9703116
Kligman AM, Plewig G Classification of acne Cutis 1976 17(3):520 2 138545
Knox JM, Owens DW. Demthethylchloretetracycline in the treatment of acne vulgaris. South Med J. 1965;58.
Knutson DD, Swinyer LJ, Smoot WH Meclocycline sulfosalicylate. Topical antibiotic agent for the treatment of acne vulgaris Cutis 1981 27(2):203 4, 208-10 6452987
Koo J The psychosocial impact of acne: patients' perceptions J Am Acad Dermatol 1995 32(5 Pt 3):S26 30 7738224
Koo JY, Smith LL Obsessive-compulsive disorders in the pediatric dermatology practice Pediatr Dermatol 1991 8(2):107 13 1923977
Koo JY, Smith LL Psychologic aspects of acne Pediatr Dermatol 1991 8(3):185 8 1836060
Korting HC, Braun-Falco O Efficacy and tolerability of combined topical treatment of acne vulgaris with tretinoin and erythromycin in general practice Drugs Exp Clin Res 1989 15(9):447 51 2534292
Korting HC, Ponce Poschl E, Klovekorn W, et al. The influence of the regular use of a soap or an acidic syndet bar on pre-acne. Infection. 1995;23:89-93. [pmid: 7622270].
Kramer HC. Similar antiphlogistic reactions after prefrontal lobotomy and treatment with chlorpromazine. J Nerv Ment Dis. 1956;123:72-78. [pmid: 13346365].
Kraning K, Odland G Prevalence, morbidity, and cost or dermatological diseases J Invest Dermatol 1979 73(Suppl):395 401
Krishnan G. Comparison of two concentrations of tretinoin solution in the topical treatment of acne vulgaris. Practitioner. 1976;216:106-9. [pmid: 131310].
Krowchuk DP, Stancin T, Keskinen R, et al The psychosocial effects of acne on adolescents Pediatr Dermatol 1991 8(4):332 8 1838809
Krowchuk DP Treating Acne: A Practical Guide for Pediatricians American Academy of Pediatrics/Adolescent Health Update 1998 11(1):1 12
Kuhlman DS, Callen JP. A comparison of clindamycin phosphate 1 percent topical lotion and placebo in the treatment of acne vulgaris. Cutis. 1986;38:203-6. [pmid: 2945704].
Kuller JM Effects on the fetus and newborn of medications commonly used during pregnancy Journal of Perinatal & Neonatal Nursing 1990 3(4):73 87 2182832
Kurokawa I, Akamatsu H, Nishijima S, et al. Clinical and bacteriologic evaluation of OPC-7251 in patients with acne: a double-blind group comparison study versus cream base. J Am Acad Dermatol. 1991;25:674-81. [pmid: 1838749].
Lafarge H, Levy PE. Evaluation economique d'une innovation medicamenteuse: le treatment de l'acne severe par Roaccutane. J d'Economie Medicale. 1987;5:117-127.
Lane P, Williamson DM. Treatment of acne vulgaris with tetracycline hydrochloride: a double-blind trial with 51 patients. Br Med J. 1969;2:76-9. [pmid: 4237796].
Langner A, Boorman GC, Stapor V, et al. Isotretinoin cream 0.05% and 0.1% in the treatment of acne vulgaris. J Dermatol Treat. 1994;5:177-180.
Lassus A. The effect of silicol gel compared with placebo on papulopustular acne and sebum production. A double-blind study. J Int Med Res. 1996;24:340-4. [pmid: 8854287].
Lassus A. Local treatment of acne. A clinical study and evaluation of the effect of different concentrations of benzoyl peroxide gel. Curr Med Res Opin. 1981;7:370-3. [pmid: 6453695].
Layton AM, Cunliffe WJ Guidelines for optimal use of isotretinoin in acne J Am Acad Dermatol 1992 27(6 Pt 2):S2 7 1460120
Layton AM, Seukeran D, Cunliffe WJ Scarred for life? Dermatology 1997 195Suppl 1:15 21; discussion 38-40 9310741
Lee ML, Cooper A Isotretinoin: cost-benefit study Australas J Dermatol 1991 32(1):17 20 1834044
Lee O, Farquhar C, Toomath R, et al. Spironolactone versus placebo or in combination with steroids for hirsutism and/or acne [Cochrane review]. In: The Cochrane Library, Issue 4, 1999. Oxford: Update Software.
Lee S, Leung CM, Wing YK, et al Acne as a risk factor for anorexia nervosa in Chinese Australian and New Zealand Journal of Psychiatry 1991 25(1):134 137 1828663
Leeming JA. Intralesional triamcinolone in the treatment of cystic acne. S Afr Med J. 1965;39:567-71. [pmid: 14338511].
Lesher JL Jr, Chalker DK, Smith JG Jr, et al. An evaluation of a 2% erythromycin ointment in the topical therapy of acne vulgaris. J Am Acad Dermatol. 1985;12:526-31. [pmid: 3157709].
Lester RS, Schachter GD, Light MJ. Isotretinoin and tetracycline in the management of severe nodulocystic acne. Int J Dermatol. 1985;24:252-7. [pmid: 3159698].
Letawe C, Boone M, Pierard GE Digital image analysis of the effect of topically applied linoleic acid on acne microcomedones Clin Exp Dermatol 1998 23(2):56 8 9692305
Leung LH A stone that kills two birds: Pantothenic acid in the treatment of acne vulgaris and obesity Journal of Orthomolecular Medicine 1997 12(2):99 114
Lever L, Marks R Current views on the aetiology, pathogenesis and treatment of acne vulgaris Drugs 1990 39(5):681 92 2141311
Levy SW. Treatment of acne with sulfamethoxazole. Skin. 1962;1:373-5. [pmid: 13930294].
Levy SW. Use of madribon in dermatological conditions, with special reference to acne. Ann NY Acad Sci. 1959;82:80-3. [pmid: 14416449].
Lewis RJ, Martin R, Tkach J Effectiveness of hexachlorophene and surgical sponges in the treatment of acne Curr Ther Res Clin Exp 1972 14(5):270 6 4260490
Leyden JJ Therapy for acne vulgaris N Engl J Med 1997 336(16):1156 62 9099661
Leyden JJ, Kaidbey K, Gans EH. The antimicrobial effects in vivo of minocycline, doxycycline and tetracycline in humans. J Dermatol Treat. 1996;7:223-225.
Leyden JJ, Marples RR, Mills OH, et al Tretinoin and antibiotic therapy in acne vulgaris South Med J 1974 67(1):20 5 4271817
Leyden JJ, Shalita AR, Saatjian GD, et al. Erythromycin 2% gel in comparison with clindamycin phosphate 1% solution in acne vulgaris. J Am Acad Dermatol. 1987;16:822-7. [pmid: 2952685].
Liddell K. Benzoyl peroxide gel in the treatment of acne vulgaris. Br J Clin Pract. 1974;28:379-82. [pmid: 4282247].
Liddell K Tetracycline and proteolytic enzymes in the treatment of acne vulgaris Practitioner 1978 221(1325):783 6 154094
Liden S, Goransson K, Odsell L Clinical evaluation in acne Acta Derm Venereol Suppl (Stockh) 1980Suppl 89:47 52
Lim CC, Presbury DG, Adamson J. A sustained-release tetracycline preparation in acne vulgaris. Practitioner. 1974;212:728-31. [pmid: 4282416].
Lim CC, Tan TC Personality, disability and acne in college students Clin Exp Dermatol 1991 16(5):371 3 1838971
Lookingbill DP, Abrams BB, Ellis CN, et al. Inocoterone and acne. The effect of a topical antiandrogen: results of a multicenter clinical trial [see comments]. Arch Dermatol. 1992;128:1197-200. [pmid: 1387778].
Lookingbill DP, Chalker DK, Lindholm JS, et al. Treatment of acne with a combination clindamycin/benzoyl peroxide gel compared with clindamycin gel, benzoyl peroxide gel and vehicle gel: combined results of two double-blind investigations. J Am Acad Dermatol. 1997;37:590-5. [pmid: 9344199].
Loveman AB, Hammond K. Triacetyloleandomycin (TAO)-its value in acne and certain pyogenic skin eruptions. J Kentucky Med Ass. 1959;57:1507-10.
Lowe NJ Managing acne in adult women Patient Care 1934 31(10):30 2
Lowney ED, Witkowski I, Simons HM, et al. Value of comedo extraction in treatment of acne ulgaris. JAMA. 1964;189:1000-2. [pmid: 14188876].
Lubowe II. Treatment of acne vulgaris with a formulation containing aluminum chlorhydroxy allantoinate. Clin Med. 1961;8:1519-22. [pmid: 15445440].
Lucas CJ. Personality of students with acne vulgaris. Br Med J. 1961;5248:354-6. [pmid: 13763958].
Lucchina LC, Kollias N, Gillies R, et al. Fluorescence photography in the evaluation of acne. J Am Acad Dermatol. 1996;35:58-63. [pmid: 8682965].
Lucky AW, Barber BL, Girman CJ, et al A multirater validation study to assess the reliability of acne lesion counting [see comments] J Am Acad Dermatol 1996 35(4):559 65 8859284
Lucky AW, Biro FM, Huster GA, et al Acne vulgaris in premenarchal girls. An early sign of puberty associated with rising levels of dehydroepiandrosterone Arch Dermatol 1994 130(3):308 14 8129408
Lucky AW, Biro FM, Huster GA, et al Acne vulgaris in early adolescent boys. Correlations with pubertal maturation and age Arch Dermatol 1991 127(2):210 6 1825016
Lucky AW, Cullen SI, Funicella T, et al Double-blind, vehicle-controlled, multicenter comparison of two 0.025% tretinoin creams in patients with acne vulgaris J Am Acad Dermatol 1998 38(4):S24 30 9555823
Lucky AW, Cullen SI, Jarratt MT, et al Comparative efficacy and safety of two 0.025% tretinoin gels: results from a multicenter double-blind, parallel study J Am Acad Dermatol 1998 38(4):S17 23 9555822
Lucky AW, Henderson TA, Olson WH, et al. Effectiveness of norgestimate and ethinyl estradiol in treating moderate acne vulgaris. J Am Acad Dermatol. 1997;37:746-54. [pmid: 9366821].
Lynchberg MC, Khoury MJ, Lammer EJ, et al Sensitivity, specificity, and positive predictive value of multiple malformations istretinion embryopathy surveillance Teratology 1990 42(5):513 9 2278026
Lyons RE. Comparative effectiveness of benzoyl peroxide and tretinoin in acne vulgaris. Int J Dermatol. 1978;17:246-51. [pmid: 148436].
MacDonald RH, Macconnell LE, Dunsmore IR. Trimethoprim-sulphamethoxazole versus placebo in acne vulgaris. Br J Clin Pract. 1972;26:97-8. [pmid: 4259578].
MacDonald RH, McGrath H, Ray SK. Clinical trial of Actinac in acne. Br J Clin Pract. 1976;30:194-6. [pmid: 136977].
MacDonald TC, Taylor F. Staphylococcus toxoid and pustular acne. Lancet. 1951;2:558-61. [pmid: 14874441].
MacDonald TM, Collins D, McGilchrist MM, et al The utilisation and economic evaluation of antibiotics prescribed in primary care J Antimicrob Chemother 1995 35(1):191 204 7768769
Maclean JG. Treatment of acne with prothipendyl. Can Med Assoc J. 1961;84:427-30. [pmid: 13764951].
Mango D, Ricci S, Manna P, et al. Clinical and hormonal effects of ethinylestradiol combined with gestodene and desogestrel in young women with acne vulgaris. Contraception. 1996;53:163-70. [pmid: 8689881].
Mantle F More than skin deep... complementary therapies have a valuable role to play in treating skin problems Nurs Times 1996 92(36):56 7
Manuel HS. Effective approach to acne problem in college students. Clin Med. 1964;71:483-9. [pmid: 15446132].
Margolis CF, Ramundo ML Acne management. Primary care physician or dermatologist? Postgrad Med 1987 82(8):139 46
Margolis DJ, Attie M, Leyden JJ Effects of isotretinoin on bone mineralization during routine therapy with isotretinoin for acne vulgaris Arch Dermatol 1996 132(7):769 74 8678568
Marks R. Acne-social impact and health education. J R Soc Med. 1985;78 Suppl 10:21-4. [pmid: 2941582].
Marsden J, Shuster S Cyclic cyproterone/ethinyloestradiol for acne [letter] Lancet 1983 2(8352):736 7 6136862
Mayer da Silva A, Gollnick H, Detmar M, et al. Effects of azelaic acid on sebaceous gland, sebum excretion rate and keratinization pattern in human skin. An in vivo and in vitro study. Acta Derm Venereol Suppl (Stockh). 1989;143:20-30. [pmid: 2475995].
McElwee NE, Schumacher MC, Johnson SC, et al An observational study of isotretinoin recipients treated for acne in a health maintenance organization Arch Dermatol 1991 127(3):341 6 1825596
Mcguiness BW, Cooper FG, Jacomb RG. Neo-medrone acne lotion in the treatment of acne vulgaris. Br J Clin Pract. 1965;19:181-4. [pmid: 14286136].
McKenzie MW. Topical clindamycin formulations for acne vulgaris: Clinical effectiveness and patient compliance. Dissertation Abstracts International. 1980;40:4231-4232.
McKenzie MW, Beck DC, Popovich NG. Topical clindamycin formulations for the treatment of acne vulgaris. An evaluation. Arch Dermatol. 1981;117:630-4. [pmid: 6456699].
Medansky RS Emotion and skin: A double blind evaluation of psychotropic agents Psychosomatics 1971 12(5):326 329 4950857
Meltzer L. Treatment of cystic acne with gamma globulin. South Med J. 1961;54:85-6. [pmid: 13769307].
Mesquita Guimaraes J, Ramos S, Tavares MR, et al. A double-blind clinical trial with a lotion containing 5% benzoyl peroxide and 2% miconazole in patients with acne vulgaris. Clin Exp Dermatol. 1989;14:357-60. [pmid: 2532986].
Michaelsson G. Oral zinc in acne. Acta Derm Venereol Suppl (Stockh). 1980;89:87-93. [pmid: 6451132].
Michaelsson G, Juhlin L, Ljunghall K. A double-blind study of the effect of zinc and oxytetracycline in acne vulgaris. Br J Dermatol. 1977;97:561-6. [pmid: 145237].
Michaelsson G, Juhlin L, Vahlquist A. Effects of oral zinc and vitamin A in acne. Arch Dermatol. 1977;113:31-6. [pmid: 137693].
Michaelsson G, Vahlquist A, Mobacken H, et al. Changes in laboratory variables induced by isotretinoin treatment of acne. Acta Derm Venereol. 1986;66:144-8. [pmid: 2424238].
Milberg IL. Clinical study in the treatment of acne vulgaris using zirconium as the base: a new concept in the control of sebum excretion. Clin Med. 1964;71:695-8. [pmid: 15446146].
Milikan LE. A double-blind study of Betadine skin cleanser in acne vulgaris. Cutis. 1976;17:394-8. [pmid: 138535].
Miller JA, Wojnarowska FT, Dowd PM, et al. Anti-androgen treatment in women with acne: a controlled trial. Br J Dermatol. 1986;114:705-16. [pmid: 2941052].
Mills OH Jr, Kligman AM. Assay of comedolytic activity in acne patients. Acta Derm Venereol. 1983;63:68-71. [pmid: 6191495].
Mills OH Jr, Kligman AM Evaluation of abrasives in acne therapy Cutis 1979 23(5):704 5 156627
Mills OH Jr, Kligman AM. Treatment of acne vulgaris with topically applied erythromycin and tretinoin. Acta Derm Venereol. 1978;58:555-7. [pmid: 83088].
Mills OH Jr, Kligman AM, Pochi P, et al. Comparing 2.5%, 5%, and 10% benzoyl peroxide on inflammatory acne vulgaris. Int J Dermatol. 1986;25:664-7. [pmid: 2948929].
Mills OH, Berger RS, Kligman AM, et al. A comparative study of Erycette (R) vs Cleocin-T (R). Adv Ther. 1992;9:14-20.
Monk BE, Almeyda JA, Caldwell IW, et al. Efficacy of low-dose cyproterone acetate compared with minocycline in the treatment of acne vulgaris. Clin Exp Dermatol. 1987;12:319-22. [pmid: 2965628].
Morganti P, Randazzo SD, Giardina A, et al. Effect of phosphatidylcholine linoleic acid-rich and glycolic acid in acne vulgaris. Journal Applied Cosmetology. 1997;15:21-32.
Morginson WJ, Eskelson YD. The role of triacetyloleandomycin in the treatment of pustular and cystic acne: a double blind study. Antibiot Ann. 1959-1960;7:657-9.
Moroni P, Bruni G. A pilot trial of a weak estrogen in the treatment of acne vulgaris in young women. Arzneimittelforschung. 1976;26:583-4. [pmid: 133690].
Morris LA, Barofsky I. Impact of risk communication on accrual, regimen, and follow-up compliance. In: Cramer JA and Spilker B, editors. Patients Compliance in Medical Practice and Clinical Trials. New York: Raven Press. 1991:57-69.
Moskop JC, Smith JL, De Ville K Ethical and legal aspects of teratogenic medications: the case of isotretinoin Journal of Clinical Ethics 1997 8(3):264 78 9436085
Motley RJ, Finlay AY How much disability is caused by acne? Clin Exp Dermatol 1989 14(3):194 8 2531637
Motley RJ, Finlay AY Practical use of a disability index in the routine management of acne Clin Exp Dermatol 1992 17(1):1 3 1424249
Muhlemann MF, Carter GD, Cream JJ, et al. Oral spironolactone: an effective treatment for acne vulgaris in women. Br J Dermatol. 1986;115:227-32. [pmid: 2943311].
Murphy JC, Petty S. Oxytetracycline treatment for acne. Lovelace Clin Rev. 1962;1:130-2. [pmid: 13936739].
Narciso JC Jr. Some psychological aspects of dermatosis. J Consult Psychol. 1952;16:199-201. [pmid: 14946285].
Nease RF Jr, Owens DK Use of influence diagrams to structure medical decisions Med Decis Making 1997 17(3):263 75 9219186
Newton JN How cost-effective is oral isotretinoin? Dermatology 1997 195Suppl 1:10 4 discussion 38-40 9310740
Newton JN, Mallon E, Klassen A, et al The effectiveness of acne treatment: an assessment by patients of the outcome of therapy Br J Dermatol 1997 137(4):563 7 9390332
Nielsen PG Treatment of female acne vulgaris with a cream containing the antiandrogen canrenone Dermatologica 1983 166(5):275 6 6223846
Noojin RO, Osment LS, Broyles JA. The treatment of pustular acne vulgaris with sulfamethoxydiazine. Curr Ther Res Clin Exp. 1964;43:684-6.
Noojin RO, Osment LS, Montgomery DR. Sulfadimethoxine in the treatment of pustular acne vulgaris. Clin Med. 1962;69:1148-50. [pmid: 15445834].
Nordin K, Fredriksson T, Rylander C. Ro 11-1430, a new retinoic acid derivative for the topical treatment of acne. Dermatologica. 1981;162:104-11. [pmid: 6454596].
Nordin K, Hallander H, Fredriksson T, et al A clinical and bacteriological evaluation of the effect of sulphamethoxazole-trimethoprim in acne vulgaris, resistant to prior therapy with tetracyclines Dermatologica 1978 157(4):245 53 150980
Norris JF, Hughes BR, Basey AJ, et al. A comparison of the effectiveness of topical tetracycline, benzoyl-peroxide gel and oral oxytetracycline in the treatment of acne. Clin Exp Dermatol. 1991;16:31-3. [pmid: 1827368].
Nurse DS Vitamin A acid in acne Australas J Dermatol 1971 12(2):108 10 4256116
O'Loughlin M. Acne in the adult female. Australas J Dermatol. 1964;14:218-22.
Oakley AM The Acne Disability Index: usefulness confirmed Australas J Dermatol 1996 37(1):37 9 8936069
Obermayer ME. Functional factors in common dermatoses. JAMA. 1943;122:862-864 1943.
Olafsson JH, Gudgeirsson J, Eggertsdottir GE, et al. Doxycycline versus minocycline in the treatment of acne vulgaris: A double-blind study. J Dermatol Treat. 1989;1:15-17.
Olansky S, McCormick GE Jr. Triacetyloleandomycin: further observations on the treatment of acne and pyodermas. Antibiot Ann. 1959-1960;7:652-6.
Olansky S, McCormick GF Jr. Alternate media in the therapy of acne vulgaris. Med Times. 1963;91:833-5. [pmid: 13939911].
Olson WH, Lippman JS, Robisch DM The duration of response to norgestimate and ethinyl estradiol in the treatment of acne vulgaris Int J Fertil Womens Med 1998 43(6):286 90 9920537
Orentreich N, Berger R. Sulfamethoxazole therapy in pustular acne. Curr Ther Res Clin Exp. 1964;15:377-80.
Orris L, Shalita AR, Sibulkin D, et al. Oral zinc therapy of acne. Absorption and clinical effect. Arch Dermatol. 1978;114:1018-20. [pmid: 150813].
Ortonne JP Oral isotretinoin treatment policy. Do we all agree? Dermatology 1997 195Suppl 1:34 7; discussion 38-40 9310744
Ott F, Bollag W, Geiger JM Oral 9-cis-retinoic acid versus 13-cis-retinoic acid in acne therapy Dermatology 1996 193(2):124 6 8884148
Pace WE. A benzoyl peroxide-sulfur cream for acne vulgaris. Can Med Assoc J. 1965;93:252-4. [pmid: 14328040].
Packman AM, Brown RH, Dunlap FE, et al Treatment of acne vulgaris: combination of 3% erythromycin and 5% benzoyl peroxide in a gel compared to clindamycin phosphate lotion Int J Dermatol 1996 35(3):209 11 8655242
Padilla RS, McCabe JM, Becker LE. Topical tetracycline hydrochloride vs. topical clindamycin phosphate in the treatment of acne: a comparative study. Int J Dermatol. 1981;20:445-8. [pmid: 6455388].
Pai IF, Wu YC, Lu YC Clinical trial of cyproterone acetate-ethinyl oestradiol compound on androgen dependent skin disorders Taiwan I Hsueh Hui Tsa Chih 1982 81(8):1048 55 6217284
Palatsi R, Hirvensalo E, Liukko P, et al. Serum total and unbound testosterone and sex hormone binding globulin (SHBG) in female acne patients treated with two different oral contraceptives. Acta Derm Venereol. 1984;64:517-23. [pmid: 6084924].
Palatsi R, Reinila M, Kivinen S. Pituitary function and DHEA-S in male acne and DHEA-S, prolactin and cortisol before and after oral contraceptive treatment in female acne. Acta Derm Venereol. 1986;66:225-30. [pmid: 2426899].
Palatsi R, Ruokonen A, Oikarinen A Isotretinoin, tetracycline and circulating hormones in acne Acta Derm Venereol 1997 77(5):394 6 9298137
Palitz LL, Milberg IL, Kantor R.I. Enovid for acne in the female. Skin. 1964;79:243-5. [pmid: 14198594].
Pandya KV. Management of acne vulgaris. J Indian Med Assoc. 1965;44:648-50. [pmid: 14326662].
Panzer JD, Poche W, Meek TJ, et al. Acne treatment: a comparative efficacy trial of clindamycin and tetracycline. Cutis. 1977;19:109-11. [pmid: 138573].
Paranjpe P, Kulkarni PH. Comparative efficacy of four Ayurvedic formulations in the treatment of acne vulgaris: a double-blind randomised placebo-controlled clinical evaluation. J Ethnopharmacol. 1995;49:127-32. [pmid: 8824737].
Parker F. A comparison of clindamycin 1% solution versus clindamycin 1% gel in the treatment of acne vulgaris. Int J Dermatol. 1987;26:121-2. [pmid: 2952611].
Parsons RJ, Wright ND, Wilson LS Evaluation of patients' compliance with medical practitioners' prescriptions: university health center experience J Am Coll Health Assoc 1980 28(6):342 5 7391420
Peacock CE, Price C, Ryan BE. Topical clindamycin (Dalacin T)* compared to oral minocycline (Minocin 50) in treatment of acne vulgaris. A randomized observer-blind controlled trial in three university student health centres. Clin Trials J. 1990;27:219-28.
Pearl A, Arroll B, Lello J, et al The impact of acne: a study of adolescents' attitudes, perception and knowledge N Z Med J 1998 111(1070):269 71 9734528
Peck GL, Olsen TG, Butkus D, et al. Isotretinoin versus placebo in the treatment of cystic acne. A randomized double-blind study. J Am Acad Dermatol. 1982;6:735-45. [pmid: 6461677].
Peck GL, Olsen TG, Yoder FW, et al Prolonged remissions of cystic and conglobate acne with 13-cis-retinoic acid N Engl J Med 1979 300(7):329 33 153472
Pedace FJ, Stoughton R. Topical retinoic acid in acne vulgaris. Br J Dermatol. 1971;84:465-9. [pmid: 4253593].
Pettit JH. Does serum gonadotrophin cure acne vulgaris?. Br Med J. 1959;1:557-8. [pmid: 13629049].
Piercehe JR. Progestational response of acne vulgaris in the female. J Natl Med Assoc. 1964;56.
Pillsbury DM, Shelley WB, Kligman AM. Textbook of Acne: morphogenesis and treatment. Philadelphia: Saunders 1956. Chapter 35, Acne, Acneiform Eruptions and Rosacea.
Plewig G. Vitamin A acid. Topical treatment in acne vulgaris. Pa Med. 1969;72:33-5. [pmid: 4243255].
Plewig G, Kligman M. Texbook of Acne: Morphogenesis and Treatment. New York: Springer-Verlag; 1975 Chapter 10, Classification of acne vulgaris.
Plewig G, Petrozzi JW, Berendes U. Double-blind study of doxycycline in acne vulgaris. Arch Dermatol. 1970;101:435-8. [pmid: 4245454].
Pochi PE Editorial: Antibiotics in acne N Engl J Med 1976 294(1):43 4 127946
Pochi PE When to refer: management of refractory acne Hospital Practice 1979 20(10):73 5 2932455
Pochi PE, Ceilley RI, Coskey RJ, et al Guidelines for prescribing isotretinoin (Accutane) in the treatment of female acne patients of childbearing potential. Acne Subgroup, Task Force on Standards of Care J Am Acad Dermatol 1988 19(5 Pt 1):
Pochi PE, Shalita AR, Strauss JS, et al Report of the Consensus Conference on Acne Classification Washington, D.C., March 24 and 25, 1990 J Am Acad Dermatol 1991 24(3):495 500 1829466
Pochi PE, Shalita AR, Whiting DA An update on acne management Patient Care 1989 23(4):85 102
Pochi PE, Bagatell FK, Ellis CN, et al. Erythromycin 2 percent gel in the treatment of acne vulgaris. Cutis. 1988;41:132-6. [pmid: 2964344].
Poulos ET, Tedesco FJ. Acne vulgaris: double-blind trial comparing tetracycline and clindamycin. Arch Dermatol. 1976;112:974-6. [pmid: 132902].
Prendiville JS, Logan RA, Russell Jones R. A comparison of dapsone with 13-cis retinoic acid in the treatment of nodular cystic acne. Clin Exp Dermatol. 1988;13:67-71. [pmid: 2975199].
Prince RA, Busch DA, Hepler CD, et al. Clinical trial of topical erythromycin in inflammatory acne. Drug Intell Clin Pharm. 1981;15:372-6. [pmid: 6456140].
Prince RA, Harris JM, Maroc JA. Comparative trial of benzoyl peroxide versus benzoyl peroxide with urea in inflammatory acne. Cutis. 1982;29:638-40, 644-5. [pmid: 6213380].
Rand S Acne lesion counts and global assessments [letter; comment] J Am Acad Dermatol 1997 37(1):
Rapaport M, Puhvel SM, Reisner RM. Evaluation of topical erythromycin and oral tetracycline in acne vulgaris. Cutis. 1982;30:122-135. [pmid: 6214377].
Ratzer MA. The influence of marriage, pregnancy and childbirth on acne vulgaris. Br J Dermatol. 1964;76:165-8. [pmid: 14140740].
Rayner C Sexuality and the other handicaps Sexuality and Disability 1980 3(3):182 186
Redmond GP, Olson WH, Lippman JS, et al. Norgestimate and ethinyl estradiol in the treatment of acne vulgaris: a randomized, placebo-controlled trial. Obstet Gynecol. 1997;89:615-22. [pmid: 9083323].
Resh W, Stoughton RB. Topically applied antibiotics in acne vulgaris. Clinical response and suppression of Corynebacterium acnes in open comedones. Arch Dermatol. 1976;112:182-184. [pmid: 134675].
Rietschel RL, Duncan SH Benzoyl peroxide reactions in an acne study group Contact Dermatitis 1982 8(5):323 6 6216050
Rietschel RL, Duncan SH Clindamycin phosphate used in combination with tretinoin in the treatment of acne Int J Dermatol 1983 22(1):41 3 6219964
Riley KA. Failure of treatment of acne vulgaris with hydro-chlorothiazide. Arch Dermatol. 1961;84.
Rivkin L, Rapaport M Clinical evaluation of a new erythromycin solution for acne vulgaris Cutis 1980 25(5):552 5 6445816
Robbins SJ. A 'self tinting' salicylic acid and parachlorometaxylenol liquid powder-base for acne therapy. Med Times. 1965;93:430-3. [pmid: 14261387].
Roberts G. Treatment of acne vulgaris with a topical ointment containing kanamycin, amphomycin and hydrocortisone (kanfotrex-bristol). Cent Afr J Med. 1964;10:23-4. [pmid: 14113848].
Robinson HM Jr. A controlled study of erythromycin in acne therapy. Bull Sch Med Univ Maryland. 1964;49:10-3. [pmid: 14104984].
Robinson HM Jr, Aton JK, Ciambotti A, et al. Topical acne therapy. South Med J. 1961;54:1105-10. [pmid: 14492906].
Robinson K, Hinegardner P, Lansing P. Development of an optimal search strategy for the retieval of controlled trials using PubMed. Abstr Workshops Sci Sess Int Cochrane Coll. 1998;6.
Robledo AA, Lopez BE, del Pino Gamboa J, et al. Multicentric comparative study of the efficacy and tolerance of clindamycin phosphate 1% topical solution and tetracycline topical solution for the treatment of acne vulgaris. Curr Ther Res Clin Exp. 1988;43:21-26.
Rollman O, Vahlquist A Oral isotretinoin (13-cis-retinoic acid) therapy in severe acne: drug and vitamin A concentrations in serum and skin J Invest Dermatol 1986 86(4):384 9 2943822
Ross CM. The treatment of acne vulgaris with dapsone. Br J Dermatol. 1961;73:367-70. [pmid: 14494150].
Roth HL. Acne vulgaris: evaluation of a medicated cleansing pad. Calif Med. 1964;100:165-7. [pmid: 14131397].
Rubinow DR, Peck GL, Squillace KM, et al Reduced anxiety and depression in cystic acne patients after successful treatment with oral isotretinoin J Am Acad Dermatol 1987 17(1):25 32 2956296
Rumsfield JA, West DP, Tse CST Isotretinoin in severe, recalcitrant cystic acne: a review Drug Intell Clin Pharm 1983 17(5):329 33 6222891
Rushton RJ. The treatment of acne vulgaris with epioestriol (Actriol). Br J Dermatol. 1962;74:91-3. [pmid: 14495355].
Sablosky L. Teenagers with acne: a survey of their attitudes towards skin problems and treatment by the physician. Amer Pract. 1961;12:515-6.
Sagher F, Tas J. Grenz ray treatment of acne vulgaris. J Invest Dermatol. 1960;35:103-6. [pmid: 14440768].
Saihan EM, Burton JL, Meyrick G, et al. The effect of a topical antibiotic preparation in acne vulgaris--a controlled clinical and laboratory study. Br J Clin Pract. 1981;35:106-9. [pmid: 6455138].
Samuelson JS. An accurate photographic method for grading acne: initial use in a double-blind clinical comparison of minocycline and tetracycline. J Am Acad Dermatol. 1985;12:461-7. [pmid: 3157706].
Samuelson JS Acne grading methods [letter] Arch Dermatol 1981 117(5):
Saurat JH Side effects of systemic retinoids and their clinical management J Am Acad Dermatol 1992 27(6 Pt 2):S23 8 1460121
Savin RC, Turner MC. Antibiotics and the placebo reaction in acne. JAMA. 1966;196:365-7. [pmid: 4222372].
Schachner L, Eaglstein W, Kittles C, et al. Topical erythromycin and zinc therapy for acne [see comments]. J Am Acad Dermatol. 1990;22:253-60. [pmid: 2138176].
Schachner L, Pestana A, Kittles C. A clinical trial comparing the safety and efficacy of a topical erythromycin-zinc formulation with a topical clindamycin formulation. J Am Acad Dermatol. 1990;22:489-495. [pmid: 2138180].
Schachter RJ, Pantel ES, Glassman GM, et al Acne vulgaris and psychologic impact on high school students N Y State J Med 1971 71(24):2886 2890 4256134
Schafer Korting M, Korting HC, Ponce Poschl E. Liposomal tretinoin for uncomplicated acne vulgaris. Clin Investig. 1994;72:1086-91.
Scheinman PL, Peck GL, Rubinow DR, et al Acute depression from isotretinoin [see comments] J Am Acad Dermatol 1990 22(6 Pt 1):1112 4 2142496
Schutte H, Cunliffe WJ, Forster RA The short-term effects of benzoyl peroxide lotion on the resolution of inflamed acne lesions Br J Dermatol 1982 106(1):91 4 6460521
Segal AE, Rogin JR. Systemic sulfonamide treatment of infected acne and other pyodermas. J Mich Med Soc. 1963;62:891-2. [pmid: 14048353].
Seukeran DC, Eady EA, Cunliffe WJ Benefit-risk assessment of acne therapies [letter; comment] Lancet 1997 349(9060):1251 2
Shahlita AR, Smith EB, Bauer E. Topical erythromycin v clindamycin therapy for acne. A multicenter, double-blind comparison. Arch Dermatol. 1984;120:351-5. [pmid: 6230999].
Shalita A, Weiss JS, Chalker DK, et al. A comparison of the efficacy and safety of adapalene gel 0.1% and tretinoin gel 0.025% in the treatment of acne vulgaris: a multicenter trial. J Am Acad Dermatol. 1996;34:482-5. [pmid: 8609263].
Shalita AR Treatment of mild and moderate acne vulgaris with salicylic acid in an alcohol-detergent vehicle Cutis 1981 28(5):556 8, 561 6458457
Shalita AR, Smith JG, Parish LC, et al. Topical nicotinamide compared with clindamycin gel in the treatment of inflammatory acne vulgaris. Int J Dermatol. 1995;34:434-7. [pmid: 7657446].
Shalita AR. Comparison of a salicylic acid cleanser and a benzoyl peroxide wash in the treatment of acne vulgaris. Clin Ther. 1989;11:264-267. [pmid: 2525420].
Sheehan-Dare RA, Papworth-Smith J, Cunliffe WJ. A double-blind comparison of topical clindamycin and oral minocycline in the treatment of acne vulgaris. Acta Derm Venereol. 1990;70:534-7. [pmid: 1981436].
Sheehan-Dare RA, Cunliffe WJ. Topical 5% biphenylacetic acid is not effective in acne. J Dermatol Treat. 1990;1.
Siegle RJ, Fekety R, Sarbone PD, et al. Effects of topical clindamycin on intestinal microflora in patients with acne. J Am Acad Dermatol. 1986;15:180-5. [pmid: 2943760].
Simpson JR, Trusted HW, Wilkinson DS, et al Clinical experience with 0.025 percent retinoic acid solution ('Retin- A') in the topical treatment of acne Curr Med Res Opin 1973 1(8):485 8 4272584
Simpson N Effect of isotretinoin on the quality of life of patients with acne Pharmacoeconomics 1994 6(2):108 13 10147436
Simpson NB. Social and economic aspects of acne and the cost-effectiveness of isotretinoin. J Dermatol Treat. 1993;4:S6-S9.
Sklar JL, Jacobson C, Rizer R, et al. Evaluation of triaz 10% gel and benzamycin in acne vulgaris. J Dermatol Treat. 1996;7:147-152.
Smit F. Minocycline versus doxycycline in the treatment of acne vulgaris. A double-blind study. Dermatologica. 1978;157:186-90. [pmid: 150346].
Smith EB, Padilla RS, McCabe JM, et al Benzoyl peroxide lotion (20 percent) in acne Cutis 1980 25(1):90 2 6444379
Smith JG Jr, Chalker DK, Wehr RF. The effectiveness of topical and oral tetracycline for acne. South Med J. 1976;69:695-7. [pmid: 132705].
Smith MA, Waterworth PM, Curwen MP. A controlled trial of oral antibiotics in the treatment of acne vulgaris. Br J Dermatol. 1962;74:86-90. [pmid: 13914345].
Sommer S, Bojar R, Cunliffe WJ, et al Investigation of the mechanism of action of 2% fusidic acid lotion in the treatment of acne vulgaris Clin Exp Dermatol 1997 22(5):211 5 9536540
Spellman MC, Pincus SH Efficacy and safety of azelaic acid and glycolic acid combination therapy compared with tretinoin therapy for acne Clin Ther 1998 20(4):711 21 9737831
Spencer MC Oral enzyme therapy in treatment of acne: a preliminary report Arch Dermatol 1965 92(6):688 9 4221211
Stankler L. Tetracycline and proteolytic enzymes combined compared with tetracycline alone in acne vulgaris. Br J Clin Pract. 1976;30:65-6. [pmid: 130921].
Stathakis V, Kilkenny M, Marks R Descriptive epidemiology of acne vulgaris in the community Australas J Dermatol 1997 38(3):115 23 9293656
Stern RS The prevalence of acne on the basis of physical examination J Am Acad Dermatol 1992 26(6):931 5 1535079
Stern RS, Nelson C The diminishing role of the dermatologist in the office-based care of cutaneous diseases J Am Acad Dermatol 1993 29(5 Pt 1):773 7 8227550
Stern RS, Pass TM, Komaroff AL Topical v systemic agent treatment for papulopustular acne. A cost- effectiveness analysis Arch Dermatol 1984 120(12):1571 8 6239593
Stoughton RB Topical or systemic antibiotics for acne Int J Dermatol 1981 20(9):592 3 6458571
Stoughton RB, Cornell RC, Gange RW, et al Double-blind comparison of topical 1 percent clindamycin phosphate (Cleocin T) and oral tetracycline 500 mg/day in the treatment of acne vulgaris Cutis 1980 26(4):424 5, 429 6448131
Stoughton RB, Resh W Topical clindamycin in the control of acne vulgaris Cutis 1976 17(3):551 4 138549
Strasburger VC Acne. What every pediatrician should know about treatment Pediatr Clin North Am 1997 44(6):1505 23 9400584
Strauss JS Isotretinoin (Accutane) for the management of severe nodulocystic acne Iowa Med 1984 74(4):170 2 6234256
Strauss JS Overview of other topical retinoids J Am Acad Dermatol 1986 15(4 Pt 2):905 6 2945845
Strauss JS, Kligman AM. Effect of x-rays on sebaceous glands of the human face: radiation therapy of acne. J Invest Dermatol. 1959;33:347-56. [pmid: 13835150].
Strauss JS, Pochi PE. Effect of cyclic progestin-estrogen therapy on sebum and acne in women. JAMA. 1964;190:815-9. [pmid: 12254865].
Strauss JS, Rapini RP, Shalita AR, et al Isotretinoin therapy for acne: results of a multicenter dose-response study J Am Acad Dermatol 1984 10(3):490 6 6233335
Strauss JS, Stranieri AM Acne treatment with topical erythromycin and zinc: effect of propionibacterium acnes and free fatty acid composition J Am Acad Dermatol 1984 11(1):86 9 6234335
Stritzler C, Frank L. Long-term oleandomycin therapy for acne. AMA Arch Derm. 1960;81:958-61. [pmid: 13835243].
Sulzberger MB, Witten VH, Steagall RW Jr. Treatment of acne vulgaris. Use of systemic antibiotics and sulfonamides. JAMA. 1960;173:1911-5. [pmid: 13835675].
Sweren RJ. A clinical trial comparing the safety and efficacy of a topical erythromycin-zinc formulation with a topical clindamycin formulation [letter; comment]. J Am Acad Dermatol. 1991;24:664-5. [pmid: 1827802].
Swinyer LJ, Baker MD, Swinyer TA, et al. A comparative study of benzoyl peroxide and clindamycin phosphate for treating acne vulgaris. Br J Dermatol. 1988;119:615-22. [pmid: 2974719].
Swinyer LJ, Swinyer TA, Britt MR. Topical agents alone in acne. A blind assessment study. JAMA. 1980;243:1640-3. [pmid: 6444678].
Taffe AM Acne treatment. A comprehensive review of pharmacotherapy Lippincotts Prim Care Pract 1997 1(1):70 87 9166611
Taylor MB Treatment of acne vulgaris: guidelines for primary care physicians Postgrad Med 1945 89(8):40 7 1828117
Thappa DM, Dogra J. Nodulocystic acne: oral gugulipid versus tetracycline. J Dermatol Treat. 1994;21:729-31.
Thiboutot DM Acne. An overview of clinical research findings Dermatol Clin 1997 15(1):97 109 9001864
Thiboutot DM An overview of acne and its treatment Cutis 1996 57(1 Suppl):8 12 8654131
Thiboutot DM, Lookingbill DP Acne: acute or chronic disease? J Am Acad Dermatol 1995 32(5 Pt 3):S2 5 7738223
Thomas DR, Raimer S, Smith EB. Comparison of topical erythromycin 1.5 percent solution versus topical clindamycin phosphate 1.0 percent solution in the treatment of acne vulgaris. Cutis. 1982;29:624-5, 628-32. [pmid: 6213379].
Thomsen RJ, Stranieri A, Knutson D, et al. Topical clindamycin treatment of acne. Clinical, surface lipid composition, and quantitative surface microbiology response. Arch Dermatol. 1980;116:1031-4. [pmid: 6448025].
Thorne EG. Long-term clinical experience with a topical retinoid. Br J Dermatol. 1992;127 Suppl 41:31-6. [pmid: 1390184].
Tong D, Peters W, Barnetson RS. Evaluation of 0.75% metronidazole gel in acne-a double-blind study. Clin Exp Dermatol. 1994;19:221-3. [pmid: 8033381].
Tucker SB, Tausend R, Cochran R, et al Comparison of topical clindamycin phosphate, benzoyl peroxide, and a combination of the two for the treatment of acne vulgaris Br J Dermatol 1984 110(4):487 92 6231942
Tye MJ, Fisher BK. Acne treated with compress and corticosteroid cream. Arch Dermatol. 1964;89:141-3. [pmid: 14070827].
Vahlquist A, Michaelsson G, Juhlin L. Acne treatment with oral zinc and vitamin A: effects on the serum levels of zinc and retinol binding protein (RBP). Acta Derm Venereol. 1978;58:437-42. [pmid: 82355].
van der Meeren HL, van der Schroeff JG, Stijnen T, et al Dose-response relationship in isotretinoin therapy for conglobate acne Dermatologica 1983 167(6):299 303 6229429
van Hoogdalem EJ, Baven TL, Spiegel-Melsen I, et al Transdermal absorption of clindamycin and tretinoin from topically applied anti-acne formulations in man Biopharm Drug Dispos 1998 19(9):563 9 9872337
Van Neste D, Tennstedt D, Decroix J. Imidazoles and benzoyl peroxide: a comparative trial of two treatment schedules. Dermatologica. 1986;172:108-12. [pmid: 2936636].
Verma KC, Saini AS, Dhamija SK. Oral zinc sulphate therapy in acne vulgaris: a double-blind trial. Acta Derm Venereol. 1980;60:337-40. [pmid: 6163281].
Vermeulen A, Rubens R. Effects of cyproterone acetate plus ethinylestradiol low dose on plasma androgens and lipids in mildly hirsute or acneic young women. Contraception. 1988;38:419-28. [pmid: 2974791].
Verschoore M, Langner A, Wolska H, et al. Efficacy and safety of CD 271 alcoholic gels in the topical treatment of acne vulgaris. Br J Dermatol. 1991;124:368-71. [pmid: 1827344].
Verschoore M, Poncet M, Czernielewski J, et al. Adapalene 0.1% gel has low skin-irritation potential. J Am Acad Dermatol. 1997;36:S104-9. [pmid: 9204086].
Wagner KD, Wagner RF Impact of acne on sexuality Medl Aspects of Hum Sex 1985 19(6):252 255
Wansker BA. Antibiotics and pustulocystic acne. A longterm, double-blind evaluation. Arch Dermatol. 1961;84:96-8. [pmid: 13783076].
Wansker BA. Norethynodrel with mestranol in the treatment of acne. South Med J. 1964;57:917-9. [pmid: 14173050].
Warren KJ, Cruz PD Jr Clinical outcome and cost analysis of isotretinoin versus conventional regimens in the treatment of moderate acne vulgaris in male patients [letter] Pediatr Dermatol 1998 15(4):329 31 9720710
Watson WH. Daytime skin care and acne control. J Am Coll Health Assoc. 1964;13:250-3. [pmid: 14229961].
Way SC. X-rays vs. other modalities in the treatment of acne vulgaris: a review of one thousand two hundred sixty-five cases. AMA Arch Derm. 1960;81:103-9. [pmid: 13843205].
Webster GF Acne vulgaris: state of the science [editorial; comment] Arch Dermatol 1999 135(9):1101 2 10490115
Webster GF Is it reasonable for a dermatologist to treat acne? Arch Dermatol 1996 132(7):819 20 8678576
Webster GF Is it reasonable for a dermatologist to treat acne? [editorial; comment] [published erratum appears in Arch Dermatol 1996;132(9):1135] Arch Dermatol 1996 132(7):819 20 8678576
Webster GF Topical tretinoin in acne therapy J Am Acad Dermatol 1998 39(2 Pt 3):S38 44 9703122
Weiler RM Adolescents' perceptions of health concerns: An exploratory study among rural midwestern youth Health Educ Behav 1997 24(3):287 299 9158974
Weimar VM, Puhl SC, Smith WH, et al. Zinc sulfate in acne vulgaris. Arch Dermatol. 1978;114:1776-8. [pmid: 153730].
Weiner AL, Cohen W. Hepatic function in acne vulgaris patients treated with triacetyloleandomycin: A preliminary report. J New Drugs. 1962;2:307-9. [pmid: 13999593].
Weismann K, Wadskov S, Sondergaard J. Oral zinc sulphate therapy for acne vulgaris. Acta Derm Venereol. 1977;57:357-60. [pmid: 70931].
Weiss JS, Shavin JS Adapalene for the treatment of acne vulgaris J Am Acad Dermatol 1998 39(2 Pt 3):S50 4 9703124
Weissmann A, Wagner A, Plewig G. Reduction of bacterial skin flora during oral treatment of severe acne with 13-cis retinoic acid. Arch Dermatol Res. 1981;270:179-183. [pmid: 6454395].
Wethered RR. Sodium fusidate in acne. Practitioner. 1964;193:802-4. [pmid: 14244392].
Wexler L. The treatment of pustular acne with sulfadimethoxine. N Y J Med. 1961;61:3110-5.
Wexler L Two controlled studies of a topical steroid preparation in the treatment of acne vulgaris Appl Ther 1968 10(7):455 7 4233597
White GM Recent findings in the epidemiologic evidence, classification, and subtypes of acne vulgaris J Am Acad Dermatol 1998 39(2 Pt 3):S34 7 9703121
Whiting DA Acne: current therapeutic recommendations Consultant 1954-1958 23(11):49 52
Wilkinson RD, Adam JE, Murray JJ, et al Benzoyl peroxide and sulfur: foundation for acne management Can Med Assoc J 1966 95(1):28 9 4223133
Williamson DM, Whitefield M A trial of a new quaternary ammonium/bromine adduct in the treatment of acne Br J Clin Pract 1978 32(4):107 12 149554
Wilson BB Acne Vulgaris Primary Care 1989 16(3):695 712 2529576
Wilson RG Office application of a new acne grading system Cutis 1980 25(1):62 4 6444378
Wirtzer AS Treatment of acne in the fee-for-service and managed care settings J Am Acad Dermatol 1995 32(5 Pt 3):S49 51 7738227
Wishart J, Villiger J Cost-benefit of isotretinoin (Roaccutane) [letter] [see comments] N Z Med J 1991 104(911):
Wishart JM. An open study of Triphasil and Diane 50 in the treatment of acne. Australas J Dermatol. 1991;32:51-4. [pmid: 1834045].
Witkowski JA, Pairsh LC, Guin JD Acne grading methods [letter] Arch Dermatol 1980 116(5):517 8 6445708
Witkowski JA, Simons HM Objective evaluation of demethylchlortetracycline hydrochloride in the treatment of acne JAMA 1966 196(5):397 400 4222373
Wittkower E. Acne vulgaris: a psychosomatic study. Br J Dermatol. 1951;63:214-223. [pmid: 14839214].
Wong RC, Kang S, Heezen JL, et al Oral ibuprofen and tetracycline for the treatment of acne vulgaris J Am Acad Dermatol 1984 11(6):1076 81 6239884
Wood AV Relaxation training and psychosomatic disorders Australian Journal of Clinical Hypnotherapy and Hypnosis 1987 Mar 8(1):51 54
Wright ET, Kyle NL, Gunter R Personality test configurations in acne vulgaris Percept Mot Skills 1970 30(1):191 201 4394479
Wright WL. Grenz ray in the treatment of acne vulgaris. controlled study. Arch Dermatol. 1964;89:417-8. [pmid: 14096364].
Wu SF, Kinder BN, Trunnell TN, et al Role of anxiety and anger in acne patients: a relationship with the severity of the disorder J Am Acad Dermatol 1988 18(2 Pt 1):325 33 2964458
Yong CC Benzoyl peroxide gel therapy in acne in Singapore Int J Dermatol 1979 18(6):485 8 158569
Zachariae H. Topical vitamin-A-acid in acne. Acta Derm Venereol Suppl (Stockh). 1980;89:65-70. [pmid: 6451128].