# References

1 Wilson BB Acne Vulgaris Primary Care 1989 16(3):695 712 2529576
2 Webster GF Is it reasonable for a dermatologist to treat acne? Arch Dermatol 1996 Jul 132(7):819 20 8678576
3 Drake LA Guidelines of care for acne vulgaris J Am Acad Dermatol 1990 22(4):676 680 2138639
4 White GM Recent findings in the epidemiologic evidence, classification, and subtypes of acne vulgaris J Am Acad Dermatol 1998 Aug 39(2 Pt 3):S34 7 9703121
5 Kraning K, Odland G. Prevalence, morbidity, and cost or dermatological diseases. J Invest Dermatol. 1979;73(Suppl):395-401.
6 Hurwitz, S Acne vulgaris: pathogenesis and management Pediatr Rev 1994 Feb 15(2):47 52; quiz 53 8159625
7 Lucky AW, Biro FM, Huster GA, et al Acne vulgaris in early adolescent boys. Correlations with pubertal maturation and age Arch Dermatol 1991 Feb 127(2):210 6 1825016
8 Fitzpatrick SB, Fujii C, Shragg GP, Rice, L Do health care needs of indigent Mexican-American, Black, and White adolescents differ? J Adolesc Health Care 1990 11(2):128 132 2318711
9 Connolly C, Bikowsky J. Dermatology Atlas of Black Skin. Merit Publishing International 1998.
10 Pillsbury DM, Shelley WB, Kligman AM. Chapter 35, Acne, Acneiform Eruptions and Rosacea. Textbook of Acne: morphogenesis and treatment. Philadelphia: Saunders 1956.
11 Thiboutot DM Acne. An overview of clinical research findings Dermatol Clin 1997 Jan 15(1):97 109 9001864
12 Lucky AW, Biro FM, Huster GA, et al Acne vulgaris in premenarchal girls. An early sign of puberty associated with rising levels of dehydroepiandrosterone Arch Dermatol 1994 Mar 130(3):308 14 8129408
13 Webster GF Acne vulgaris: state of the science [editorial; comment] Arch Dermatol 1999 Sep 135(9):1101 2 10490115
14 Karvonen SL Acne fulminans: report of clinical findings and treatment of twenty-four patients J Am Acad Dermatol 1993 Apr 28(4):572 9 7681856
15 Cotterill JA, Cunliffe WJ Suicide in dermatological patients Br J Dermatol 1997 Aug 137(2):246 50 9292074
16 Garrie SA, Garrie EV Anxiety and skin diseases Cutis 1978 Aug 22(2):205 8 150966
17 Lim, CC, Tan TC Personality, disability and acne in college students Clin Exp Dermatol 1991 Sep 16(5):371 3 1838971
18 Gupta MA, Gupta AK, Schork NJ, et al Psychiatric aspects of the treatment of mild to moderate facial acne. Some preliminary observations Int J Dermatol 1990 Dec 29(10):719 21 2148562
19 Wu SF, Kinder BN, Trunnell TN, Fulton JE Role of anxiety and anger in acne patients: a relationship with the severity of the disorder J Am Acad Dermatol 1988 Feb 18(2 Pt 1):325 33 2964458
20 Lee ML, Cooper A Isotretinoin: cost-benefit study Australas J Dermatol 1991 32(1):17 20 1834044
21 Bergfeld WF The evaluation and management of acne: economic considerations J Am Acad Dermatol 1995 32(5 Pt 3):S52 6 7738228
22 Hurwitz, S Acne vulgaris. Current concepts of pathogenesis and treatment Am J Dis Child 1979 May 133(5):536 44 155397
23 Nease RF Jr, Owens DK Use of influence diagrams to structure medical decisions Med Decis Making 1997 Jul-1997 Sep 17(3):263 75
24 Robinson K, Hinegardner P, Lansing P. Development of an optimal search strategy for the retieval of controlled trials using PubMed. Abstr Workshops Sci Sess Int Cochrane Coll. 1998;6.
25 Johnson R, Nusbaum BP, Horwitz SN, Frost P Transfer of topically applied tetracycline in various vehicles Arch Dermatol 1983 Aug 119(8):660 3 6870319
26 Cunliffe WJ, Grosshans E, Belaich S, et al. A comparison of the efficacy and safety of lymecycline and minocycline in patients with moderately severe acne vulgaris. Eur J Dermatol. 1998;8:161-6. [pmid: 9649660].
27 Korting HC, Ponce Poschl E, Klovekorn W, et al. The influence of the regular use of a soap or an acidic syndet bar on pre-acne. Infection. 1995;23:89-93. [pmid: 7622270].
28 Mills OH Jr, Kligman AM Evaluation of abrasives in acne therapy Cutis 1979 May 23(5):704 5 156627
29 Milikan LE. A double-blind study of Betadine skin cleanser in acne vulgaris. Cutis. 1976;17:394-8. [pmid: 138535].
30 Lassus A. The effect of silicol gel compared with placebo on papulopustular acne and sebum production. A double-blind study. J Int Med Res. 1996;24:340-4. [pmid: 8854287].
31 Cunliffe WJ, Holland KT. Clinical and laboratory studies on treatment with 20% azelaic acid cream for acne. Acta Derm Venereol Suppl (Stockh). 1989;143:31-4. [pmid: 2528256].
32 Katsambas A, Graupe K, Stratigos J. Clinical studies of 20% azelaic acid cream in the treatment of acne vulgaris. Comparison with vehicle and topical tretinoin. Acta Derm Venereol Suppl (Stockh). 1989;143:35-9. [pmid: 2528257].
33 Cavicchini S, Caputo R. Long-term treatment of acne with 20% azelaic acid cream. Acta Derm Venereol Suppl (Stockh). 1989;143:40-4. [pmid: 2528258].
34 Eady EA, Burke BM, Pulling K, Cunliffe WJ. The benefit of 2% salicylic acid lotion in acne - A placebo-controlled study. J Dermatol Treat. 1996;7:93-96.
35 Roth HL. Acne vulgaris: evaluation of a medicated cleansing pad. Calif Med. 1964 Mar;100:165-7. [pmid: 14131397].
36 Delaney J, Ferrara RJ, Robarge I. Treatment of acne vulgaris with polythionates incorporated in a vanishing cream. J Mich Med Soc. 1959 Aug;58:1259-61.
37 Elstein W. Topical deodorized polysulfides. Broadscope acne therapy. Cutis. 1981;28:468-72. [pmid: 6458456].
38 Kirton V. Evaluation of new preparation for the treatment of acne vulgaris. Br J Clin Pract. 1967;21:127-8. [pmid: 4227626].
39 Hjorth N, Storm D, Dela K. Topical anhydrous aluminum chloride formulation in the treatment of acne vulgaris: a double-blind study. Cutis. 1985;35:499-500. [pmid: 3159552].
40 Mcguiness BW, Cooper FG, Jacomb RG. Neo-medrone acne lotion in the treatment of acne vulgaris. Br J Clin Pract. 1965 Mar;19:181-4.
41 Hunt MJ, Barnetson RS. A comparative study of gluconolactone versus benzoyl peroxide in the treatment of acne. Australas J Dermatol. 1992;33:131-4. [pmid: 1303072].
42 Morganti P, Randazzo SD, Giardina A, et al. Effect of phosphatidylcholine linoleic acid-rich and glycolic acid in acne vulgaris. Journal Applied Cosmetology. 1997;15:21-32.
43 Becker LE, Bergstresser PR, Whiting DA, et al. Topical clindamycin therapy for acne vulgaris. A cooperative clinical study. Arch Dermatol. 1981;117:482-5. [pmid: 6455095].
44 Braathen LR Topical clindamycin versus oral tetracycline and placebo in acne vulgaris Scand J Infect Dis Suppl 1984 43(Suppl.):71 5 6242073
45 Ellis CN, Gammon WR, Stone DZ, Heezen-Wehner JL. A comparison of Cleocin T Solution, Cleocin T Gel, and placebo in the treatment of acne vulgaris. Cutis. 1988;42:245-7. [pmid: 2971512].
46 Lookingbill DP, Chalker DK, Lindholm JS, et al. Treatment of acne with a combination clindamycin/benzoyl peroxide gel compared with clindamycin gel, benzoyl peroxide gel and vehicle gel: combined results of two double-blind investigations. J Am Acad Dermatol. 1997;37:590-5. [pmid: 9344199].
47 Kuhlman DS, Callen JP. A comparison of clindamycin phosphate 1 percent topical lotion and placebo in the treatment of acne vulgaris. Cutis. 1986;38:203-6. [pmid: 2945704].
48 Lucchina LC, Kollias N, Gillies R, et al. Fluorescence photography in the evaluation of acne. J Am Acad Dermatol. 1996;35:58-63. [pmid: 8682965].
49 Thomsen RJ, Stranieri A, Knutson D, Strauss JS. Topical clindamycin treatment of acne. Clinical, surface lipid composition, and quantitative surface microbiology response. Arch Dermatol. 1980;116:1031-4. [pmid: 6448025].
50 Guin JD Treatment of acne vulgaris with topical clindamycin phosphate: a double-blind study Int J Dermatol 1981 May 20(4):286 8 6453849
51 Shalita AR, Smith JG, Parish LC, et al. Topical nicotinamide compared with clindamycin gel in the treatment of inflammatory acne vulgaris. Int J Dermatol. 1995;34:434-7. [pmid: 7657446].
52 Guin, JD. Topical clindamycin: a double-blind study comparing clindamycin phosphate with clindamycin hydrochloride. Int J Dermatol. 1979;18:164-6. [pmid: 154479].
53 McKenzie MW, Beck DC, Popovich NG. Topical clindamycin formulations for the treatment of acne vulgaris. An evaluation. Arch Dermatol. 1981;117:630-4. [pmid: 6456699].
54 Goltz RW, Coryell GM, Schnieders JR, Neidert GL. A comparison of Cleocin T 1 percent solution and Cleocin T 1 percent lotion in the treatment of acne vulgaris. Cutis. 1985;36:265-8. [pmid: 2932307].
55 Parker F. A comparison of clindamycin 1% solution versus clindamycin 1% gel in the treatment of acne vulgaris. Int J Dermatol. 1987;26:121-2. [pmid: 2952611].
56 Henderson TA, Olson WH, Leach AD. A single-blind, randomized comparison of erythromycin pledgets and clindamycin lotion in the treatment of mild to moderate facial acne vulgaris. Adv Ther. 1995;12:172-177.
57 Leyden JJ, Shalita AR, Saatjian GD, Sefton J. Erythromycin 2% gel in comparison with clindamycin phosphate 1% solution in acne vulgaris. J Am Acad Dermatol. 1987;16:822-7. [pmid: 2952685].
58 Mills OH, Berger RS, Kligman AM, et al. A comparative study of Erycette (R) vs Cleocin-T (R). Adv Ther. 1992;9:14-20.
59 Shalita AR, Smith EB, Bauer E. Topical erythromycin v clindamycin therapy for acne. A multicenter, double-blind comparison. Arch Dermatol. 1984;120:351-5. [pmid: 6230999].
60 Thomas DR, Raimer S, Smith EB. Comparison of topical erythromycin 1.5 percent solution versus topical clindamycin phosphate 1.0 percent solution in the treatment of acne vulgaris. Cutis. 1982;29:624-5, 628-32. [pmid: 6213379].
61 Padilla RS, McCabe JM, Becker LE. Topical tetracycline hydrochloride vs. topical clindamycin phosphate in the treatment of acne: a comparative study. Int J Dermatol. 1981;20:445-8. [pmid: 6455388].
62 Robledo AA, Lopez BE, del Pino Gamboa J, et al. Multicentric comparative study of the efficacy and tolerance of clindamycin phosphate 1% topical solution and tetracycline topical solution for the treatment of acne vulgaris. Curr Ther Res Clin Exp. 1988;43:21-26.
63 Swinyer LJ, Baker MD, Swinyer TA, Mills OH Jr. A comparative study of benzoyl peroxide and clindamycin phosphate for treating acne vulgaris. Br J Dermatol. 1988;119:615-22. [pmid: 2974719].
64 Tucker SB, Tausend R, Cochran R, Flannigan SA Comparison of topical clindamycin phosphate, benzoyl peroxide, and a combination of the two for the treatment of acne vulgaris Br J Dermatol 1984 Apr 110(4):487 92 6231942
65 Jones EL, Crumley AF. Topical erythromycin vs blank vehicle in a multiclinic acne study. Arch Dermatol. 1981;117:551-3. [pmid: 6457568].
66 Lesher JL Jr, Chalker DK, Smith JG Jr, et al. An evaluation of a 2% erythromycin ointment in the topical therapy of acne vulgaris. J Am Acad Dermatol. 1985;12:526-31. [pmid: 3157709].
67 Pochi PE, Bagatell FK, Ellis CN, et al. Erythromycin 2 percent gel in the treatment of acne vulgaris. Cutis. 1988;41:132-6. [pmid: 2964344].
68 Dobson RL, Belknap BS Topical erythromycin solution in acne. Results of a multiclinic trial J Am Acad Dermatol 1980 Nov 3(5):478 82 6452463
69 Prince RA, Busch DA, Hepler CD, Feldick HG. Clinical trial of topical erythromycin in inflammatory acne. Drug Intell Clin Pharm. 1981;15:372-6. [pmid: 6456140].
70 Groot WP de, Prakken J, Verbeek A, Woerdeman MJ. The value of grenz-ray therapy for acne vulgaris. Dermatologica. 1963;126:319-25. [pmid: 13950714].
71 Hellgren L, Vincent J Topical erythromycin for acne vulgaris Dermatologica 1980 161(6):409 14 6452297
72 Rivkin L, Rapaport M Clinical evaluation of a new erythromycin solution for acne vulgaris Cutis 1980 May 25(5):552 5 6445816
73 Burke B, Eady EA, Cunliffe WJ Benzoyl peroxide versus topical erythromycin in the treatment of acne vulgaris Br J Dermatol 1983 Feb 108(2):199 204 6218815
74 Hansted B, Jorgensen J, Reymann, F, Christiansen J. Fucidin(Reg.trademark) cream for topical treatment of acne vulgaris. Curr Ther Res. 1985;37:249-253.
75 Sommer S, Bojar R, Cunliffe WJ, et al Investigation of the mechanism of action of 2% fusidic acid lotion in the treatment of acne vulgaris Clin Exp Dermatol 1997 Sep 22(5):211 5 9536540
76 Knutson DD, Swinyer LJ, Smoot WH Meclocycline sulfosalicylate. Topical antibiotic agent for the treatment of acne vulgaris Cutis 1981 Feb 27(2):203 4, 208-10 6452987
77 Borglund E, Kristensen B, Larsson-Stymne B, et al. Topical meclocycline sulfosalicylate, benzoyl peroxide, and a combination of the two in the treatment of acne vulgaris. Acta Derm Venereol. 1991;71:175-8. [pmid: 1675534].
78 Tong D, Peters W, Barnetson RS. Evaluation of 0.75% metronidazole gel in acne-a double-blind study. Clin Exp Dermatol. 1994;19:221-3. [pmid: 8033381].
79 Robinson HM Jr, Aton JK, Ciambotti A, Roberts D. Topical acne therapy. South Med J. 1961 Oct;54:1105-10.
80 Anderson RL, Cook CH, Smith DE. The effect of oral and topical tetracycline on acne severity and on surface lipid composition. J Invest Dermatol. 1976;66:172-7. [pmid: 129494].
81 Blaney DJ, Cook CH. Topical use of tetracycline in the treatment of acne: a double-blind study comparing topical and oral tetracycline therapy and placebo. Arch Dermatol. 1976;112:971-3. [pmid: 132901].
82 Burton J. A placebo-controlled study to evaluate the efficacy of topical tetracycline and oral tetracycline in the treatment of mild to moderate acne. Dermatology Research Group. J Int Med Res. 1990;18:94-103. [pmid: 2140332].
83 Smith JG Jr, Chalker DK, Wehr RF. The effectiveness of topical and oral tetracycline for acne. South Med J. 1976;69:695-7. [pmid: 132705].
84 Norris JF, Hughes BR, Basey AJ, Cunliffe WJ. A comparison of the effectiveness of topical tetracycline, benzoyl-peroxide gel and oral oxytetracycline in the treatment of acne. Clin Exp Dermatol. 1991;16:31-3. [pmid: 1827368].
85 Bettley FR, Dale TL. The local treatment of acne. Br J Clin Pract. 1976;30:67-9. [pmid: 130922].
86 Mills OH Jr, Kligman AM, Pochi P, Comite H. Comparing 2.5%, 5%, and 10% benzoyl peroxide on inflammatory acne vulgaris. Int J Dermatol. 1986;25:664-7. [pmid: 2948929].
87 Hughes BR, Norris JF, Cunliffe WJ. A double-blind evaluation of topical isotretinoin 0.05%, benzoyl peroxide gel 5% and placebo in patients with acne. Clin Exp Dermatol. 1992;17:165-8. [pmid: 1451291].
88 Smith EB, Padilla RS, McCabe JM, Becker LE Benzoyl peroxide lotion (20 percent) in acne Cutis 1980 Jan 25(1):90 2 6444379
89 Jaffe GV, Grimshaw JJ, Constad D. Benzoyl peroxide in the treatment of acne vulgaris: a double-blind, multi-centre comparative study of 'Quinoderm' cream and 'Quinoderm' cream with hydrocortisone versus their base vehicle alone and a benzoyl peroxide only gel preparation. Curr Med Res Opin. 1989;11:453-62. [pmid: 2528439].
90 Ede M. A double-blind, comparative study of benzoyl peroxide, benzoyl peroxide-chlorhydroxyquinoline, benzoyl peroxide-chlorhydroxyquinoline-hydrocortisone, and placebo lotions in acne. Curr Ther Res Clin Exp. 1973;15:624-9. [pmid: 4270828].
91 Shalita AR. Comparison of a salicylic acid cleanser and a benzoyl peroxide wash in the treatment of acne vulgaris. Clin Ther. 1989;11:264-267. [pmid: 2525420].
92 Plewig G. Vitamin A acid. Topical treatment in acne vulgaris. Pa Med. 1969;72:33-5. [pmid: 4243255].
93 Yong CC Benzoyl peroxide gel therapy in acne in Singapore Int J Dermatol 1979 Jul 18(6):485 8 158569
94 Lyons RE. Comparative effectiveness of benzoyl peroxide and tretinoin in acne vulgaris. Int J Dermatol. 1978;17:246-51. [pmid: 148436].
95 Fyrand O, Jakobsen HB. Water-based versus alcohol-based benzoyl peroxide preparations in the treatment of acne vulgaris. Dermatologica. 1986;172:263-7. [pmid: 2943613].
96 Cunliffe WJ, Holland KT. The effect of benzoyl peroxide on acne. Acta Derm Venereol. 1981;61:267-9. [pmid: 6167116].
97 Handojo I The combined use of topical benzoyl peroxide and tretinoin in the treatment of acne vulgaris Int J Dermatol 1979 Jul-1979 Aug 18(6):489 96 158570
98 Prince RA, Harris JM, Maroc JA. Comparative trial of benzoyl peroxide versus benzoyl peroxide with urea in inflammatory acne. Cutis. 1982;29:638-40, 644-5. [pmid: 6213380].
99 Sklar JL, Jacobson C, Rizer R, Gans EH. Evaluation of triaz 10% gel and benzamycin in acne vulgaris. J Dermatol Treat. 1996;7:147-152.
100 Ashurst PJ. The treatment of acne. A comparison of 'quinoderm' and 'quinoderm hydrocortisone' creams. Practitioner. 1964 Aug;193:192-4. [pmid: 14199634].
101 Danto JL, Maddin WS, Stewart WD, Nelson AJ. A controlled trial of benzoyl peroxide and precipitated sulfur cream in acne vulgaris. Appl Ther. 1966;8:624-5. [pmid: 4223595].
102 Chalker DK, Shalita A, Smith JG Jr, Swann RW A double-blind study of the effectiveness of a 3% erythromycin and 5% benzoyl peroxide combination in the treatment of acne vulgaris J Am Acad Dermatol 1983 Dec 9(6):933 6 6227643
103 Packman AM, Brown RH, Dunlap FE, et al Treatment of acne vulgaris: combination of 3% erythromycin and 5% benzoyl peroxide in a gel compared to clindamycin phosphate lotion Int J Dermatol 1996 35(3):209 11 8655242
104 Chu A, Huber FJ, Plott RT. The comparative efficacy of benzoyl peroxide 5%/erythromycin 3% gel and erythromycin 4%/zinc 1.2% solution in the treatment of acne vulgaris. Br J Dermatol. 1997;136:235-8. [pmid: 9068739].
105 Gamborg-Nielsen P. Topical metronidazole gel. Use in acne vulgaris. Int J Dermatol. 1991;30:662-6. [pmid: 1834598].
106 Degreef H, Vanden BG. Double-blind evaluation of miconazole-benzoyl peroxide combination for the topical treatment of acne vulgaris. Dermatologica. 1982;164:201-208. [pmid: 6211379].
107 Fluckiger R, Furrer HJ, Rufli T. Efficacy and tolerance of a miconazole-benzoyl peroxide cream combination versus a benzoyl peroxide gel in the topical treatment of acne vulgaris. Dermatologica. 1988;177:109-14. [pmid: 2971582].
108 Mesquita Guimaraes J, Ramos S, Tavares MR, Carvalho MR. A double-blind clinical trial with a lotion containing 5% benzoyl peroxide and 2% miconazole in patients with acne vulgaris. Clin Exp Dermatol. 1989;14:357-60. [pmid: 2532986].
109 Van Neste D, Tennstedt D, Decroix J. Imidazoles and benzoyl peroxide: a comparative trial of two treatment schedules. Dermatologica. 1986;172:108-12. [pmid: 2936636].
110 Cunliffe W, Caputo R, Dreno B, et al. Clinical efficacy and safety comparison of adapalene gel and tretinoin gel in the treatment of acne vulgaris: Europe and U.S. multicenter trials. J Am Acad Dermatol. 1997;36:S126-34. [pmid: 9204091].
111 Verschoore M, Langner A, Wolska H, et al. Efficacy and safety of CD 271 alcoholic gels in the topical treatment of acne vulgaris. Br J Dermatol. 1991;124:368-71. [pmid: 1827344].
112 Dunlap FE, Baker MD, Plott RT, Verschoore M. Adapalene 0.1% gel has low skin irritation potential even when applied immediately after washing. Br J Dermatol. 1998;139 Suppl 52:23-5.
113 Caron D, Sorba V, Kerrouche N, Clucas A. Split-face comparison of adapalene 0.1% gel and tretinoin 0.025% gel in acne patients. J Am Acad Dermatol. 1997;36:S110-2. [pmid: 9204087].
114 Dunlap FE, Mills OH, Tuley MR, et al. Adapalene 0.1% gel for the treatment of acne vulgaris: its superiority compared to tretinoin 0.025% cream in skin tolerance and patient preference. Br J Dermatol. 1998;139 Suppl 52:17-22.
115 Clucas A, Verschoore M, Sorba V, et al. Adapalene 0.1% gel is better tolerated than tretinoin 0.025% gel in acne patients. J Am Acad Dermatol. 1997;36:S116-8. [pmid: 9204089].
116 Ellis CN, Millikan LE, Smith EB, et al. Comparison of adapalene 0.1% solution and tretinoin 0.025% gel in the topical treatment of acne vulgaris. Br J Dermatol. 1998;139 Suppl 52:41-7. [pmid: 9990420].
117 Grosshans E, Marks R, Mascaro JM, et al. Evaluation of clinical efficacy and safety of adapalene 0.1% gel versus tretinoin 0.025% gel in the treatment of acne vulgaris, with particular reference to the onset of action and impact on quality of life. Br J Dermatol. 1998;139 Suppl 52:26-33. [pmid: 9990418].
118 Shalita A, Weiss JS, Chalker DK, et al. A comparison of the efficacy and safety of adapalene gel 0.1% and tretinoin gel 0.025% in the treatment of acne vulgaris: a multicenter trial. J Am Acad Dermatol. 1996;34:482-5. [pmid: 8609263].
119 Galvin SA, Gilbert R, Baker M, et al. Comparative tolerance of adapalene 0.1% gel and six different tretinoin formulations. Br J Dermatol. 1998;139 Suppl 52:34-40. [pmid: 9990419].
120 Chalker DK, Lesher JL Jr, Smith JG Jr, et al. Efficacy of topical isotretinoin 0.05% gel in acne vulgaris: results of a multicenter, double-blind investigation. J Am Acad Dermatol. 1987;17:251-4. [pmid: 2957398].
121 Langner A, Boorman GC, Stapor V, et al. Isotretinoin cream 0.05% and 0.1% in the treatment of acne vulgaris. J Dermatol Treat. 1994;5:177-180.
122 Dominguez J, Hojyo MT, Celayo JL, et al Topical isotretinoin vs. topical retinoic acid in the treatment of acne vulgaris Int J Dermatol 1998 Jan 37(1):54 5 9522243
123 Elbaum DJ. Comparison of the stability of topical isotretinoin and topical tretinoin and their efficacy in acne. J Am Acad Dermatol. 1988;19:486-91. [pmid: 2971693].
124 Christiansen J, Gadborg E, Hattel T, et al. The retinoic acid derivative Ro 11-1430 (Tasmaderm) in patients with acne vulgaris not tolerating retinoic acid. A controlled multicenter trial against placebo. Dermatologica. 1979;159:466-70. [pmid: 159841].
125 Christiansen J, Holm P, Reymann F. The retinoic acid derivative Ro 11-1430 in Acne vulgaris. A controlled multicenter trial against retinoic acid. Dermatologica. 1977;154:219-27. [pmid: 140824].
126 Nordin K, Fredriksson T, Rylander C. Ro 11-1430, a new retinoic acid derivative for the topical treatment of acne. Dermatologica. 1981;162:104-11. [pmid: 6454596].
127 Christiansen J, Holm P, Reymann F. Treatment of acne vulgaris with the retinoic acid derivative Ro 11-1430. A controlled clinical trial against retinoic acid. Dermatologica. 1976;153:172-6. [pmid: 138608].
128 Gunning DB, Barua AB, Lloyd RA, Olson JA. Retinoyl beta-glucuronide: A nontoxic retinoid for the topical treatment of acne. J Dermatol Treat. 1994;5:181-185.
129 Christiansen JV, Gadborg E, Ludvigsen K, et al. Topical tretinoin, vitamin A acid (Airol) in acne vulgaris. A controlled clinical trial. Dermatologica. 1974;148:82-9. [pmid: 4276190].
130 Krishnan G. Comparison of two concentrations of tretinoin solution in the topical treatment of acne vulgaris. Practitioner. 1976;216:106-9. [pmid: 131310].
131 Lucky AW, Cullen SI, Jarratt MT, Quigley JW Comparative efficacy and safety of two 0.025% tretinoin gels: results from a multicenter double-blind, parallel study J Am Acad Dermatol 1998 Apr 38(4):S17 23 9555822
132 Lucky AW, Cullen SI, Funicella T, et al Double-blind, vehicle-controlled, multicenter comparison of two 0.025% tretinoin creams in patients with acne vulgaris J Am Acad Dermatol 1998 Apr 38(4):S24 30 9555823
133 Pedace FJ, Stoughton R. Topical retinoic acid in acne vulgaris. Br J Dermatol. 1971;84:465-9. [pmid: 4253593].
134 De Bersaques J Topical vitamin A acid. Review of the literature and results of a clinical trial in acne Arch Belg Dermatol Syphiligr 1972 Oct-1972 Dec 28(4):315 34 4274476
135 Bucknall JH, Murdoch PN. Comparison of tretinoin solution and benzoyl peroxide lotion in the treatment of acne vulgaris. Curr Med Res Opin. 1977;5:266-8. [pmid: 162728].
136 Spellman MC, Pincus SH Efficacy and safety of azelaic acid and glycolic acid combination therapy compared with tretinoin therapy for acne Clin Ther 1998 Aug 20(4):711 21 9737831
137 Schafer Korting M, Korting HC, Ponce Poschl E. Liposomal tretinoin for uncomplicated acne vulgaris. Clin Investig. 1994;72:1086-91.
138 Anonymous. Retinoic acid in the treatment of acne. A report from the General Practitioner Research Group. Practitioner. 1974;213:387-90. [pmid: 4278852].
139 Brookes DB, Moffitt RM, Sheil LP, et al. Comparison of Tretinoin and a composite formulation in the treatment of acne. Br J Clin Pract. 1978;32:349-52. [pmid: 153763].
140 Brandt H, Attila P, Ahokas T, et al. Erythromycin acistrate - An alternative oral treatment for acne. J Dermatol Treat. 1994;5:3-5.
141 Bradford LG, Montes LF. Topical application of vitamin A acid in acne vulgaris. South Med J. 1974;67:683-7. [pmid: 4275274].
142 Hughes H, Brown BW, Lawlis GF, Fulton JE Jr. Treatment of acne vulgaris by biofeedback relaxation and cognitive imagery. J Psychosom Res. 1983;27:185-91. [pmid: 6224928].
143 Mills OH Jr, Kligman AM. Treatment of acne vulgaris with topically applied erythromycin and tretinoin. Acta Derm Venereol. 1978;58:555-7. [pmid: 83088].
144 Cambazard F. Clinical efficacy of Velac, a new tretinoin and clindamycin phosphate gel in acne vulgaris. J Eur Acad Dermatol Venereol. 1998;11 Suppl 1:S20-7;discussion S28-9. [pmid: 9891905].
145 Rietschel RL, Duncan SH Clindamycin phosphate used in combination with tretinoin in the treatment of acne Int J Dermatol 1983Jan-1983 Feb 22(1):41 3
146 Christian GL, Krueger GG. Clindamycin vs placebo as adjunctive therapy in moderately severe acne. Arch Dermatol. 1975;111:997-1000. [pmid: 134670].
147 Panzer JD, Poche W, Meek TJ, et al. Acne treatment: a comparative efficacy trial of clindamycin and tetracycline. Cutis. 1977;19:109-11. [pmid: 138573].
148 Poulos ET, Tedesco FJ. Acne vulgaris: double-blind trial comparing tetracycline and clindamycin. Arch Dermatol. 1976;112:974-6. [pmid: 132902].
149 Hicks JH. Demethylchloretracycline: a double-blind study in the treatment of acne with attention to side-effects noted. South Med J. 1962 Apr;55:357-60. [pmid: 13907192].
150 Knox JM, Owens DW. Demthethylchloretetracycline in the treatment of acne vulgaris. South Med J. 1965 Aug;58.
151 Smith MA, Waterworth PM, Curwen MP. A controlled trial of oral antibiotics in the treatment of acne vulgaris. Br J Dermatol. 1962 Mar;74:86-90.
152 Crounse RG. The response of acne to placebos and antibiotics. JAMA. 1965 Sep;193:906-10. [pmid: 14341135].
153 Cornbleet T. Comparison of demethychlortetracycline and tetracycline in acne. Arch Dermatol. 1964 Jan;89:144-6. [pmid: 14070828].
154 Plewig G, Petrozzi JW, Berendes U. Double-blind study of doxycycline in acne vulgaris. Arch Dermatol. 1970;101:435-8. [pmid: 4245454].
155 Adams J, Thorn P. Topical fusidic acid versus peroral doxycycline in the treatment of patients with acne vulgaris of the face. Curr Ther Res Clin Exp. 1991;50:268-273.
156 Bleeker J, Hellgren L, Vincent J. Effect of systemic erythromycin stearate on the inflammatory lesions and skin surface fatty acids in acne vulgaris. Dermatologica. 1981;162:342-9. [pmid: 6454598].
157 Olafsson JH, Gudgeirsson J, Eggertsdottir GE, Kristjansson F. Doxycycline versus minocycline in the treatment of acne vulgaris: A double-blind study. J Dermatol Treat. 1989;1:15-17.
158 Smit F. Minocycline versus doxycycline in the treatment of acne vulgaris. A double-blind study. Dermatologica. 1978;157:186-90. [pmid: 150346].
159 Harrison PV A comparison of doxycycline and minocycline in the treatment of acne vulgaris Clin Exp Dermatol 1988 Jul 13(4):242 4 2977578
160 Bleeker J. Tolerance and efficacy of erythromycin stearate tablets versus enteric-coated erythromycin base capsules in the treatment of patients with acne vulgaris. J Int Med Res. 1983;11:38-41. [pmid: 6219902].
161 Wansker BA. Antibiotics and pustulocystic acne. A longterm, double-blind evaluation. Arch Dermatol. 1961 Jul;84:96-8. [pmid: 13783076].
162 Al Mishari MA. Clinical and bacteriological evaluation of tetracycline and erythromycin in acne vulgaris. Clin Ther. 1987;9:273-80. [pmid: 2955899].
163 Gammon WR, Meyer C, Lantis S, et al. Comparative efficacy of oral erythromycin versus oral tetracycline in the treatment of acne vulgaris. A double-blind study. J Am Acad Dermatol. 1986;14:183-6. [pmid: 2936772].
164 Akamatsu H, Nishijima S, Akamatsu M, et al. Clinical evaluation of roxithromycin in patients with acne. J Int Med Res. 1996;24:109-14. [pmid: 8674787].
165 Morginson WJ, Eskelson YD. The role of triacetyloleandomycin in the treatment of pustular and cystic acne: a double blind study. Antibiot Ann. 1959;7:657-9. [pmid: 14424141].
166 Hersle K, Gisslen H. Minocycline in acne vulgaris: a double-blind study. Curr Ther Res Clin Exp. 1976;19:339-42. [pmid: 131678].
167 Peacock CE, Price C, Ryan BE. Topical clindamycin (Dalacin T)* compared to oral minocycline (Minocin 50) in treatment of acne vulgaris. A randomized observer-blind controlled trial in three university student health centres. Clin Trials J. 1990;27:219-28.
168 Sheehan-Dare RA, Papworth-Smith J, Cunliffe WJ. A double-blind comparison of topical clindamycin and oral minocycline in the treatment of acne vulgaris. Acta Derm Venereol. 1990;70:534-7. [pmid: 1981436].
169 Cullen SI, Cohan RH. Minocycline therapy in acne vulgaris. Cutis. 1976;17:1208-10, 1214. [pmid: 138560].
170 Hubbell CG, Hobbs ER, Rist T, White JW Jr Efficacy of minocycline compared with tetracycline in treatment of acne vulgaris Arch Dermatol 1982 Dec 118(12):989 92 6216858
171 Samuelson JS. An accurate photographic method for grading acne: initial use in a double-blind clinical comparison of minocycline and tetracycline. J Am Acad Dermatol. 1985;12:461-7. [pmid: 3157706].
172 Murphy JC, Petty S. Oxytetracycline treatment for acne. Lovelace Clin Rev. 1962 Dec;1:130-2.
173 Harcup JW, Cooper J. The treatment of acne vulgaris in general practice. A double-blind assessment of co-trimoxazole and tetracycline. Practitioner. 1980;224:747-50. [pmid: 6448998].
174 Gibson JR, Darley CR, Harvey SG, Barth J. Oral trimethoprim versus oxytetracycline in the treatment of inflammatory acne vulgaris. Br J Dermatol. 1982;107:221-224. [pmid: 6213255].
175 Hersle K. Trimethoprim-sulphamethoxazole in acne vulgaris. A double-blind study. Dermatologica. 1972;145:187-91. [pmid: 4269363].
176 MacDonald RH, Macconnell LE, Dunsmore IR. Trimethoprim-sulphamethoxazole versus placebo in acne vulgaris. Br J Clin Pract. 1972;26:97-8. [pmid: 4259578].
177 Cahn MM,Levy EJ. The use of sulfadimethoxine (madribon) in the treatment of papulopustular and cystic acne vulgaris. Ann NY Acad Sci. 1959 Sep;82:84-91.
178 Cornbleet T. Long-term therapy of acne with tetracycline. Arch Dermatol. 1961 Mar;83:414-6. [pmid: 13695560].
179 Lane P, Williamson DM. Treatment of acne vulgaris with tetracycline hydrochloride: a double-blind trial with 51 patients. Br Med J. 1969;2:76-9. [pmid: 4237796].
180 Gratton D, Raymond GP, Guertin-Larochelle S, et al Topical clindamycin versus systemic tetracycline in the treatment of acne. Results of a multiclinic trial J Am Acad Dermatol 1982 Jul 7(1):50 3 6213682
181 Wong RC, Kang S, Heezen JL, et al Oral ibuprofen and tetracycline for the treatment of acne vulgaris J Am Acad Dermatol 1984 Dec 11(6):1076 81 6239884
182 Borglund E, Hagermark O, Nord CE Impact of topical clindamycin and systemic tetracycline on the skin and colon microflora in patients with acne vulgaris Scand J Infect Dis Suppl 1984 43(Suppl.):76 81 6242074
183 Katsambas A, Towarky AA, Stratigos J. Topical clindamycin phosphate compared with oral tetracycline in the treatment of acne vulgaris. Br J Dermatol. 1987;116:387-91. [pmid: 2952156].
184 Stoughton RB, Cornell RC, Gange RW, Walter JF Double-blind comparison of topical 1 percent clindamycin phosphate (Cleocin T) and oral tetracycline 500 mg/day in the treatment of acne vulgaris Cutis 1980 Oct 26(4):424 5, 429 6448131
185 Rapaport M, Puhvel SM, Reisner RM. Evaluation of topical erythromycin and oral tetracycline in acne vulgaris. Cutis. 1982;30:122-135. [pmid: 6214377].
186 Bladon PT, Burke BM, Cunliffe WJ, et al. Topical azelaic acid and the treatment of acne: a clinical and laboratory comparison with oral tetracycline. Br J Dermatol. 1986;114:493-9. [pmid: 2938615].
187 Hjorth N, Graupe K. Azelaic acid for the treatment of acne. A clinical comparison with oral tetracycline. Acta Derm Venereol Suppl(Stockh). 1989;143:45-8. [pmid: 2528259].
188 Hjorth N, Schmidt H, Thomsen K, Dela K. Meclosorb, a new topical antibiotic agent in the treatment of acne vulgaris: a double-blind clinical study. Acta Derm Venereol. 1984;64:354-7. [pmid: 6209900].
189 Lim CC, Presbury DG, Adamson J. A sustained-release tetracycline preparation in acne vulgaris. Practitioner. 1974;212:728-31. [pmid: 4282416].
190 Stankler L. Tetracycline and proteolytic enzymes combined compared with tetracycline alone in acne vulgaris. Br J Clin Pract. 1976;30:65-6. [pmid: 130921].
191 Savin RC, Turner MC. Antibiotics and the placebo reaction in acne. JAMA. 1966;196:365-7. [pmid: 4222372].
192 Ross CM. The treatment of acne vulgaris with dapsone. Br J Dermatol. 1961 Oct;73:367-70. [pmid: 14494150].
193 Wethered RR. Sodium fusidate in acne. Practitioner. 1964 Dec;193:802-4. [pmid: 14244392].
194 Gandola M, Argenziano G, Barba C, et al. Topical vitamin A acid in the treatment of acne vulgaris (a controlled multicenter trial). Arch Dermatol Res. 1976;255:129-38. [pmid: 132142].
195 Swinyer LJ, Swinyer TA, Britt MR. Topical agents alone in acne. A blind assessment study. JAMA. 1980;243:1640-3. [pmid: 6444678].
196 Christiansen JV, Gadborg E, Ludvigsen K, et al. Topical vitamin A acid (Airol) and systemic oxytetracycline in the treatment of acne vulgaris. A controlled clinical trial. Dermatologica. 1974;149:121-8.
197 Peck GL, Olsen TG, Butkus D, et al. Isotretinoin versus placebo in the treatment of cystic acne. A randomized double-blind study. J Am Acad Dermatol. 1982;6:735-45. [pmid: 6461677].
198 Prendiville JS, Logan RA, Russell Jones R. A comparison of dapsone with 13-cis retinoic acid in the treatment of nodular cystic acne. Clin Exp Dermatol. 1988;13:67-71. [pmid: 2975199].
199 Lester RS, Schachter GD, Light MJ. Isotretinoin and tetracycline in the management of severe nodulocystic acne. Int J Dermatol. 1985;24:252-7. [pmid: 3159698].
200 Geiger JM, Hommel L, Harms M, Saurat JH. Oral 13-cis retinoic acid is superior to 9-cis retinoic acid in sebosuppression in human beings. J Am Acad Dermatol. 1996;34:513-5. [pmid: 8609271].
201 Goldstein JA, Socha-Szott A, Thomsen RJ, et al Comparative effect of isotretinoin and etretinate on acne and sebaceous gland secretion J Am Acad Dermatol 1982 Apr 6(4 Pt 2 Suppl):760 5 6461679
202 Al Mishari MA. A study of isotretinoin (Roaccutan) in nodulocystic acne. Clin Trials J. 1986;23:1-5.
203 Jones DH, King K, Miller AJ, Cunliffe WJ. A dose-response study of I3-cis-retinoic acid in acne vulgaris. Br J Dermatol. 1983;108:333-43. [pmid: 6219690].
204 van der Meeren HL, van der Schroeff JG, Stijnen T, et al Dose-response relationship in isotretinoin therapy for conglobate acne Dermatologica 1983 167(6):299 303 6229429
205 Strauss JS, Rapini RP, Shalita AR, et al Isotretinoin therapy for acne: results of a multicenter dose-response study J Am Acad Dermatol 1984 Mar 10(3):490 6 6233335
206 Farrell LN, Strauss JS, Stranieri AM The treatment of severe cystic acne with 13-cis-retinoic acid. Evaluation of sebum production and the clinical response in a multiple dose trial J Am Acad Dermatol 1980 Dec 3(6):602 11 6451637
207 King K, Jones DH, Daltrey DC, Cunliffe WJ A double-blind study of the effects of 13-cis-retinoic acid on acne, sebum excretion rate and microbial population Br J Dermatol 1982 Nov 107(5):583 90 6215056
208 Anonymous. Vitamin A in acne vulgaris: report by the South-East Scotland Faculty of the College of General Practitioners. Br Med J. 1963;2:294-6. [pmid: 20789943].
209 Michaelsson G, Juhlin L, Vahlquist A. Effects of oral zinc and vitamin A in acne. Arch Dermatol. 1977;113:31-6. [pmid: 137693].
210 Gruber DM, Sator MO, Joura EA, et al Topical cyproterone acetate treatment in women with acne: a placebo-controlled trial Arch Dermatol 1998 Apr 134(4):459 63 9554298
211 Monk BE, Almeyda JA, Caldwell IW, et al. Efficacy of low-dose cyproterone acetate compared with minocycline in the treatment of acne vulgaris. Clin Exp Dermatol. 1987;12:319-22. [pmid: 2965628].
212 Greenwood R, Brummitt L, Burke B, Cunliffe WJ. Acne: double blind clinical and laboratory trial of tetracycline, oestrogen-cyproterone acetate, and combined treatment. Br Med J Clin Res Ed. 1985;291:1231-5.
213 Carlborg L. Cyproterone acetate versus levonorgestrel combined with ethinyl estradiol in the treatment of acne. Results of a multicenter study. Acta Obstet Gynecol Scand. 1986;Suppl 134:29-32.
214 Colver GB, Mortimer PS, Dawber RP. Cyproterone acetate and two doses of oestrogen in female acne; a double-blind comparison. Br J Dermatol. 1988;118:95-9. [pmid: 2963663].
215 Fugere P, Percival-Smith RK, Lussier-Cacan S, et al. Cyproterone acetate/ethinyl estradiol in the treatment of acne. A comparative dose-response study of the estrogen component. Contraception. 1990;42:225-34. [pmid: 2150795].
216 Miller JA, Wojnarowska FT, Dowd PM, et al. Anti-androgen treatment in women with acne: a controlled trial. Br J Dermatol. 1986;114:705-16. [pmid: 2941052].
217 Charoenvisal C, Thaipisuttikul Y, Pinjaroen S, et al. Effects on acne of two oral contraceptives containing desogestrel and cyproterone acetate. Int J Fertil Menopausal Stud. 1996;41:423-9. [pmid: 8894800].
218 Dieben TO, Vromans L, Theeuwes A, Bennink HJ. The effects of CTR-24, a biphasic oral contraceptive combination, compared to Diane-35 in women with acne. Contraception. 1994;50:373-82. [pmid: 7813225].
219 Erkkola R, Hirvonen E, Luikku J, et al. Ovulation inhibitors containing cyproterone acetate or desogestrel in the treatment of hyperandrogenic symptoms. Acta Obstet Gynecol Scand. 1990;69:61-5. [pmid: 2140663].
220 Mango D, Ricci S, Manna P, et al. Clinical and hormonal effects of ethinylestradiol combined with gestodene and desogestrel in young women with acne vulgaris. Contraception. 1996;53:163-70. [pmid: 8689881].
221 Palatsi R, Reinila M, Kivinen S. Pituitary function and DHEA-S in male acne and DHEA-S, prolactin and cortisol before and after oral contraceptive treatment in female acne. Acta Derm Venereol. 1986;66:225-30. [pmid: 2426899].
222 Palatsi R, Hirvensalo E, Liukko P, et al. Serum total and unbound testosterone and sex hormone binding globulin (SHBG) in female acne patients treated with two different oral contraceptives. Acta Derm Venereol. 1984;64:517-23. [pmid: 6084924].
223 Hatwal A, Bhatt RP, Agrawal JK, et al. Spironolactone and cimetidine in treatment of acne. Acta Derm Venereol. 1988;68:84-7. [pmid: 2449021].
224 Muhlemann MF, Carter GD, Cream JJ, Wise P. Oral spironolactone: an effective treatment for acne vulgaris in women. Br J Dermatol. 1986;115:227-32. [pmid: 2943311].
225 Goodfellow A, Alaghband-Zadeh J, Carter G, et al. Oral spironolactone improves acne vulgaris and reduces sebum excretion. Br J Dermatol. 1984;111:209-214. [pmid: 6235834].
226 Adams RM, Burdick KH. An antiandrogen delta 1 chlormadinone acetate in acne: lack of effect topically. Acta Derm Venereol. 1970;50:479-80. [pmid: 4099161].
227 Becker FT, Bronstein SB, Jacobson C, et al. Clinical evaluation of 16-epiestriol-3-allyl ether in acne vulgaris. A collaborative study. Arch Dermatol. 1965 Feb;91:155-8.
228 Rushton RJ. The treatment of acne vulgaris with epioestriol (Actriol). Br J Dermatol. 1962 Mar;74:91-3. [pmid: 14495355].
229 Lookingbill DP, Abrams BB, Ellis CN, et al. Inocoterone and acne. The effect of a topical antiandrogen: results of a multicenter clinical trial [see comments]. Arch Dermatol. 1992;128:1197-200. [pmid: 1387778].
230 Lucky AW, Henderson TA, Olson WH, et al. Effectiveness of norgestimate and ethinyl estradiol in treating moderate acne vulgaris. J Am Acad Dermatol. 1997;37:746-54. [pmid: 9366821].
231 Redmond GP, Olson WH, Lippman JS,et al. Norgestimate and ethinyl estradiol in the treatment of acne vulgaris: a randomized, placebo-controlled trial. Obstet Gynecol. 1997;89:615-22. [pmid: 9083323].
232 Moroni P, Bruni G. A pilot trial of a weak estrogen in the treatment of acne vulgaris in young women. Arzneimittelforschung. 1976;26:583-4. [pmid: 133690].
233 Pettit JH. Does serum gonadotrophin cure acne vulgaris?. Br Med J. 1959;1:557-8. [pmid: 13629049].
234 Paranjpe P, Kulkarni PH. Comparative efficacy of four Ayurvedic formulations in the treatment of acne vulgaris: a double-blind randomised placebo-controlled clinical evaluation. J Ethnopharmacol. 1995;49:127-32. [pmid: 8824737].
235 Thappa DM, Dogra J. Nodulocystic acne: oral gugulipid versus tetracycline. J Dermatol Treat. 1994;21:729-31.
236 Dunlop KJ, Barnetson RS. A comparative study of isolutrol versus benzoyl peroxide in the treatment of acne. Australas J Dermatol. 1995;36:13-5. [pmid: 7763215].
237 Balambal R, Thiruvengadam KV, Kameswarant L, et al. Ocimum basilicum in acne vulgaris-a controlled comparison with a standard regime. J Assoc Physicians of India. 1985;33:507-8. [pmid: 2932427].
238 Bassett IB, Pannowitz DL, Barnetson RS. A comparative study of tea-tree oil versus benzoyl peroxide in the treatment of acne. Med J Aust. 1990;153:455-8. [pmid: 2145499].
239 Hull SM, Cunliffe WJ. The use of a corticosteroid cream for immediate reduction in the clinical signs of acne vulgaris. Acta Derm Venereol. 1989;69:452-3. [pmid: 2572120].
240 Ereaux LP. A new lotion for the treatment of acne vulgaris. Can Med Assoc J. 1965 Jan;92:157-9. [pmid: 14232189].
241 Wexler L Two controlled studies of a topical steroid preparation in the treatment of acne vulgaris Appl Ther 1968 Jul 10(7):455 7 4233597
242 Kern AB. Gamma-globulin in treatment of acne and psoriasis. Arch Dermatol. 1962 May;85:623-4. [pmid: 14455276].
243 Ashorn R, Uotila A, Kuokkanen K, et al. Cellular immunity in acne vulgaris during transfer factor treatment. Ann Clin Res. 1985;17:152-5. [pmid: 2934019].
244 MacDonald TC, Taylor F. Staphylococcus toxoid and pustular acne. Lancet. 1951;2:558-61. [pmid: 14874441].
245 Saihan EM, Burton JL, Meyrick G, et al. The effect of a topical antibiotic preparation in acne vulgaris-a controlled clinical and laboratory study. Br J Clin Pract. 1981;35:106-9. [pmid: 6455138].
246 MacDonald RH, McGrath H, Ray SK. Clinical trial of Actinac in acne. Br J Clin Pract. 1976;30:194-6. [pmid: 136977].
247 Guerrier CJ, Thornton EJ. Double-blind comparison of two similar lotion formulations, one without and the other with hydrocortisone acetate ('Actinac') in the treatment of acne vulgaris. Curr Med Res Opin. 1980;6:377-9. [pmid: 6444861].
248 Fraser NB, Main RA, Stewart TW, Thornton EJ. Treatment of acne vulgaris comparing two similar lotion formulations, one with ('Actinac') and one without chloramphenicol. Curr Med Res Opin. 1980;6:461-5. [pmid: 6444862].
249 Cunliffe WJ, Burke B, Dodman B. Chloramphenicol and benzoyl peroxide in acne. A double-blind clinical study. Practitioner. 1980;224:952-4. [pmid: 6449698].
250 Jelliffe AM, Soutter C, Meara RH. An investigation into the treatment of acne vulgaris with Grenz x-rays. Br J Dermatol. 1969;81:617-20. [pmid: 4240710].
251 Wright WL. Grenz ray in the treatment of acne vulgaris. controlled study. Arch Dermatol. 1964 Mar;89:417-8. [pmid: 14096364].
252 Lowney ED, Witkowski I, Simons HM, Zagula ZW. Value of comedo extraction in treatment of acne ulgaris. JAMA. 1964 Sep;189:1000-2.
253 Bottomley WW, Yip J, Knaggs H, Cunliffe WJ Treatment of closed comedones-comparisons of fulguration with topical tretinoin and electrocautery with fulguration Dermatology 1993 186(4):253 7 8513189
254 Flanders PA, McNamara JR Enhancing acne medication compliance: a comparison of strategies Behav Res Ther 1985 23(2):225 7 3159380
255 Jelinek JE. Hydrochlorothiazide and the control of premenstrual exacerbation of acne. Arch Dermatol. 1972;105:79-80. [pmid: 4257912].
256 Riley KA. Failure of treatment of acne vulgaris with hydro-chlorothiazide. Arch Dermatol. 1961 Aug;84.
257 Flinn JH. The treatment of acne with tolbutamide. Student Med. 1961 Feb;9:234-7.
258 Cochran RJ, Tucker SB, Flannigan SA. Topical zinc therapy for acne vulgaris. Int J Dermatol. 1985;24:188-90. [pmid: 3158620].
259 Agrawal P, Singh PK, Pandey SS, Singh G. Oral zinc in acne vulgaris (a double blind evaluation). Indian J Dermatol Venereol Leprol. 1985;51:38-39.
260 Orris L, Shalita AR, Sibulkin D, et al. Oral zinc therapy of acne. Absorption and clinical effect. Arch Dermatol. 1978;114:1018-20. [pmid: 150813].
261 LidenS, Goransson K, Odsell L. Clinical evaluation in acne. Acta Derm Venereol Suppl (Stockh). 1980;Suppl 89:47-52. [pmid: 6451126].
262 Weismann K, Wadskov S, Sondergaard J. Oral zinc sulphate therapy for acne vulgaris. Acta Derm Venereol. 1977;57:357-60. [pmid: 70931].
263 Dreno B, Amblard P, Agache P, et al. Low doses of zinc gluconate for inflammatory acne. Acta Derm Venereol. 1989;69:541-3. [pmid: 2575335].
264 Goransson K, Liden S, Odsell L. Oral zinc in acne vulgaris: a clinical and methodological study. Acta Derm Venereol. 1978;58:443-8. [pmid: 82356].
265 Verma KC, Saini AS, Dhamija SK. Oral zinc sulphate therapy in acne vulgaris: a double-blind trial. Acta Derm Venereol. 1980;60:337-40. [pmid: 6163281].
266 Weimar VM, Puhl SC, Smith WH, tenBroeke JE. Zinc sulfate in acne vulgaris. Arch Dermatol. 1978;114:1776-8. [pmid: 153730].
267 Hillstrom L, Pettersson L, Hellbe L, et al. Comparison of oral treatment with zinc sulphate and placebo in acne vulgaris. Br J Dermatol. 1977;97:679-84.
268 Cunliffe WJ, Burke B, Dodman B, Gould DJ. A double-blind trial of a zinc ulphate/citrate complex and tetracycline in the treatment of acne vulgaris. Br J Dermatol. 1979;101:321-5. [pmid: 159714].
269 Feucht CL, Allen BS, Chalker DK, Smith JG Jr Topical erythromycin with zinc in acne. A double-blind controlled study J Am Acad Dermatol 1980 Nov 3(5):483 91 6452464
270 Schachner L, Eaglstein W, Kittles C, Mertz P. Topical erythromycin and zinc therapy for acne [see comments]. J Am Acad Dermatol. 1990;22:253-60. [pmid: 2138176].
271 Bojar RA, Eady EA, Jones CE, et al. Inhibition of erythromycin-resistant propionibacteria on the skin of acne patients by topical erythromycin with and without zinc. Br J Dermatol. 1994;130:329-36. [pmid: 8148274].
272 Habbema L, Koopmans B, Menke HE, et al. A 4% erythromycin and zinc combination (Zineryt) versus 2% erythromycin (Eryderm) in acne vulgaris: a randomized, double-blind comparative study. Br J Dermatol. 1989;121:497-502. [pmid: 2533878].
273 Schachner L, Pestana A, Kittles C. A clinical trial comparing the safety and efficacy of a topical erythromycin-zinc formulation with a topical clindamycin formulation. J Am Acad Dermatol. 1990;22:489-495. [pmid: 2138180].
274 Allen BS, Smith JG Jr Various parameters for grading acne vulgaris Arch Dermatol 1982 Jan 118(1):23 5 6460474
275 Burke BM, Cunliffe WJ The assessment of acne vulgaris-the Leeds technique Br J Dermatol 1984 Jul 111(1):83 92
276 Cook CH, Centner RL, Michaels SE An acne grading method using photographic standards Arch Dermatol 1979 May 115(5):571 5 156006
277 Strauss JS, Stranieri AM Acne treatment with topical erythromycin and zinc: effect of propionibacterium acnes and free fatty acid composition J Am Acad Dermatol 1984 11(1):86 9 6234335