# Conclusions

The following discussion is organized around our findings, characterizing the state of the acne literature, stating overarching conclusions from the evidence synthesis, providing answers to our primary and secondary questions as the evidence allows, describing limitations of the conclusions, and pointing to future research.

## Characteristics of the Acne Clinical Research Literature

The literature regarding the treatment of acne vulgaris is characterized by a wide range of treatments, outcomes, study designs, and methods of assessment. These characteristics render synthesis of evidence difficult. We chose to focus on evidence presented in controlled clinical trials as the most efficient and defensible method for identifying which treatments are superior to others.

The 274 trials included in our review do not build toward an evidence-based consensus on the most effective process of treatment for acne vulgaris. Of the 250 treatment comparisons, 14 (5.6 percent) provided Level A evidence, 102 (41 percent) provided Level B evidence, and 134 (54 percent) provided Level C evidence (see Table 15). The trials provide a relatively disconnected series of comparisons among over 140 individual treatments. These trials provided limited information about subjects, focused on short-term outcomes, and rarely presented evidence related to the longer-term outcomes that are of greatest interest to patients: scarring, psychological morbidity, and the costs of treatment. Of trials included, 74 percent reported data on the age of the subjects, 13 percent reported phase of care at study entry, 8 percent reported race, and none reported on sexual maturity rating. We identified 25 assessment schemes for acne severity and 505 distinctly named outcomes. Less than 1 percent of trials addressed psychological effects. None reported outcomes related to costs of treatment. Four trials stratified results by gender and only three trials stratified results based on acne type or severity. No trials stratified their results with respect to degree or type of prior therapy. Such stratification is especially needed in trials where baseline acne severity ranged from mild to severe. Relating these trials to one another and drawing generalizable conclusions is impossible.

Table 15. Levels of evidence for comparison by treatment class

Treatment class | Number of comparisons by evidence level
Treatment class | A | B | C | Total
Cleanser (topical) | 0 | 0 | 6 | 6
Keratolytic (topical) | 1 | 9 | 10 | 20
Anti-bacterial (topical) | 3 | 20 | 11 | 34
Anti-bacterial/keratolytic (topical) | 2 | 19 | 19 | 40
Retinoid (topical) | 4 | 11 | 8 | 23
Anti-bacterial/retinoid (topical) | 0 | 2 | 2 | 4
Anti-bacterial (oral) | 1 | 22 | 25 | 48
Anti-bacterial (oral)/keratolytic | 0 | 1 | 2 | 3
Anti-bacterial (oral)/retinoid | 1 | 1 | 1 | 3
Retinoid (oral) | 0 | 1 | 8 | 9
Anti-androgen | 2 | 6 | 15 | 23
Other | 0 | 10 | 27 | 37
TOTAL | 14 | 102 | 134 | 250

Some arms are represented more than once because they employed more than one treatment.

In our report, we present the evidence as we encountered it in our reading of the literature. To enhance comparability across studies, we have attempted to classify subjects studied in terms of acne severity and have grouped outcomes at consistent time points where possible. We have grouped individual treatments by treatment class.

## Overarching Conclusions

Of the 14 comparisons with Level A evidence, half refer to trials where mild or moderate acne was studied; only one refers to patients with moderate to severe acne; and the remainder, to studies where acne severity could not be ascertained. The majority of these are efficacy results - comparison to vehicle or placebo, rather than to some standard of care.

The results are sparse, and, in some cases, surprising. There are no cleanser or keratolytic products in the list of Level A evidence comparisons. Of the topical anti-bacterials, clindamycin and erythromycin demonstrate evidence of superiority in mild/moderate acne over vehicle. The evidence alone suggests that topical tetracycline is no better than vehicle. The treatment mainstay benzoyl peroxide has both anti-bacterial and keratolytic activity, and the evidence indicates effectiveness with respect to vehicle, although the severity context is not explicit. The evidence suggests that the three topical retinoids, tretinoin, adapalene, and motretinide are equally effective. Of the oral anti-bacterials, the evidence is clear only for tetracycline. Surprisingly, oral isotretinoin does not appear on this list, although it is generally perceived by clinicians, including the reviewers of this report, as the most potent acne treatment. This absence, and others, may result from limitations of our review, including bias introduced through the exclusion of non-English language reports of trials. In the case of isotretinoin, this absence is also a function of limiting the review to controlled trials as such trials are difficult to design for isotretinoin because of the side effect pattern seen. Of the anti-androgens, the birth-control pill norgestimate/ethinyl estradiol was demonstrated more effective than placebo. No comparison of the "miscellaneous" class is represented in this group of comparisons with Level A evidence.

There were 102 comparisons of Level B evidence. In these comparisons, expert opinion is especially necessary to evaluate the implications for clinical care. In the case of the 134 comparisons of Level C evidence, our results suggest that further research is required to evaluate the place of those treatments in clinical care.

Table 15 categorizes the levels of evidence for the primary comparisons by treatment class and Table 16 lists the 14 comparisons for which there was Level A evidence.

Table 16. Comparisons with Level A evidence

Treatment class | Index | Severity | Target treatment | Relative efficacy | Comparator Treatment | Evidence Level | Comments
Keratolytic | B.07.02 | | Aluminum chlorhydroxide/sulfur (topical) | > | Vehicle (topical) | A
Anti-bacterial (topical) | C.01.01 | Mild/mod | Clindamycin (topical) | > | Vehicle (topical) | A | Clindamycin phosphate and hydrochloride results combined
| C.03.01 | Mild/mod | Erythromycin (topical) | > | Vehicle (topical) | A | Especially inflammatory
| C.08.01 | Mild/mod | Tetracycline (topical) | = | Vehicle (topical) | A
Anti-bacterial/keratolytic (topical) | D.01.01 | | Benzoyl peroxide (topical) | > | Vehicle (topical) | A
| D.01.09 | Mild/mod | Benzoyl peroxide (topical) | = | Benzoyl peroxide (topical) | A
Retinoid (topical) | E.01.02 | | Adapalene (topical) | = | Tretinoin (topical) | A | Evidence B that adapalene more effective for non-inflammatory
| E.02.01 | Mild/mod | Isotretinoin (topical) | > | Vehicle (topical) | A
| E.03.03 | | Motretinide (topical) | = | Tretinoin (topical) | A
| E.05.01 | Mild/mod | Tretinoin (topical) | > | Vehicle (topical) | A | Evidence type A for non-inflammatory; type B for inflammatory.
Anti-bacterial (oral) | H.08.01 | | Tetracycline (oral) | > | Placebo (oral) | A
Anti-bacterial (oral)/retinoid (topical) | J.01.02 | | Oxytetracycline (oral)/vitamin A (topical) | = | Oxytetracycline (oral) | A
Anti-androgen | M.01.05 | Mod/sev | Cyproterone/ethinyl estradiol (0.05) (oral) | = | Cyproterone/ethinyl estradiol (0.035) (oral) | A
| M.04.09 | Mild/mod | Norgestimate/ethinyl estradiol (oral) | > | Placebo (oral) | A

Note: Some arms are represented more than once because they employed more than one treatment.

## Answers to Specific Questions

### Primary Questions

#### 1. What Treatments Are Effective in the Management of Acne?

The variable study quality, as well as the noncomparability of studies due to lack of standardization, prevented us from performing quantitative meta-analyses to answer this question, which was our initial intent. In particular, we cannot make general statements about classes of treatment.

Many trials documented decreases in lesion counts with respect to baseline. However, because improvements from baseline were documented in both the active and placebo arms of many trials, we deemed treatment was "effective" only if it was deemed so in comparison to another treatment.

These conclusions are all based on severity or lesion-count based outcomes. As noted in Chapter 4, only two trials reported on psychological outcomes, beyond globally assessed patient preference.

There were few trials involving procedural, or nonmedical, treatment and the level of evidence for these trials was rated at Level C. No trials addressed diet.

#### 2. What is the Responsiveness of Acne to First-line, Second-line, and Referral Treatments?

Although clinicians and practice guidelines often discuss management of acne using this approach, the literature is not organized to answer this question. Investigators were not systematic in evaluating subjects' prior therapy. There is no basis from controlled trials to judge the efficacy of any treatment in relation to the sequence of therapy.

#### 3. What Are the Side Effects of Treatment?

The variability in the literature affects our ability to make firm statements about adverse effects. There were 88 comparisons concerning adverse effects provided in the controlled trials. Of these, five provided enough evidence to be rated as Level A; they are shown in Table 17. The evidence suggests that topical clindamycin and erythromycin have a similar rate of side effect severity that leads to patients dropping out. The evidence further suggests that, of the retinoids, tretinoin and topical isotretinoin both cause a higher rate of local reactions than vehicle and that motretinide leads to more local reactions than does tretinoin, and that tretinoin leads to more local reactions than does azelaic acid.

Table 17. Comparisons with Level A side effects evidence

Treatment class | Index | Target treatment | Side effects | Comparator treatment | Side effects | Relative side effects | Level of evidence | Comments
Anti-bacterial (topical) | C.01.04 | Clindamycin (topical) | Withdrew: 0/264 | Erythromycin (topical) | Withdrew (0.4%: 1/252) | = | A
Retinoid (topical) | E.02.01 | Isotretinoin (0.05%) (topical) | ** | Vehicle | ** | > | A | Erythema and peeling scores give significant P-values between arms
| E.03.03 | Motretinide (topical) | ** | Tretinoin | ** | > | A | Local reactions
| E.05.01 | Tretinoin (topical) | ** | Vehicle | ** | > | A | Local reactions
| E.05.04 | Tretinoin (topical) | Erythema (27%: 48/181); scaling (29%:52/181) | Azelaic acid | Erythema (15%: 27/177); scaling (14%: 24/177) | > | A

Readers are directed to package inserts and post-marketing data that provide further information concerning possible adverse effects. This is especially important for the teratogenic oral isotretinoin. Because appropriate exclusions were made, the teratogenicity of isotretinoin was not documented in the controlled trials reviewed.

### Secondary Questions

Because of the volume of literature available, this review focused on controlled clinical trials, rather than observational, laboratory, or other designs. Answers to our secondary questions require such designs (e.g., epidemiological observational studies for the residuum of untreated acne). Because of our focus, this report cannot be definitive on such issues as the true teratogenicity risk of isotretinoin, or the risk of depression in patients treated with oral retinoids.

#### What Baseline Characteristics Raise the Likelihood of Acne?

None of the controlled trials related evidence on risk factors for the development of acne.

#### What Care Do Patients Provide for Themselves at Home?

We reviewed trials specifically for locus of care but found none where "home" was the focus of care. It may be that this type of question is best addressed by other study designs that were not included in this evidence review.

#### How Effective Is Initial Home Care?

None of the reviewed trials provided information addressing this question.

#### What Is the Presentation of Acne to Physicians?

The term "presentation" suggests ways of describing acne and its natural history. These are acne duration, lesion type and count, severity, and prior therapy. Only 40 trials (14 percent) provided data on acne duration in describing their study sample at baseline. Most studies provided some information about lesion type, count, or severity. However, because these were controlled trials, where patients volunteered or were recruited in unstated ways, we do not know if the acne experienced by these subjects present the experience of all patients, and we therefore cannot say how these findings generalize. In some cases, the acne may be recent, in which case high spontaneous remission ("placebo") rates may be seen, while in others, it may be only subjects with refractory acne that are referred and recruited. A few trials included information on what treatments had been received prior to enrollment. No study quantified this information, and none stratified their results based on prior treatment. There are no standard ways of documenting "refractory" acne.

Also implicit in this question is the issue of how acne presents to dermatologists as opposed to primary care providers. Only 29 studies had patients seen in primary care offices or health clinics; so our data cannot provide a generalizable description of the patients seen in primary care.

#### How Compliant Are Patients With Their Treatment?

Measuring compliance is difficult in acne studies. The most commonly used method is to require the volunteers to bring back the used containers of medication at the time of a study visit. However, one never knows if the subjects are emptying the containers at home in order to demonstrate compliance or otherwise not taking the medication as prescribed and few of the studies documented even attempting any measure of compliance. Seventy-four trials (27 percent) provided information to conclude that they monitored compliance prospectively and only 39 of these provided some documentation of the degree of compliance (36 saying 80 percent compliance or greater and 3 trials reporting 50-80 percent compliance).

#### What Is the Residuum of Untreated Acne? Of Treated Acne?

Only 15 studies observed their subjects for more than 6 months: Trial 52,^ 214 ^ Trial 70,^ 36 ^ Trial 86,^ 219 ^ Trial 97,^ 215 ^ Trial 115,^ 212 ^ Trial 123,^ 128 ^ Trial 154,^ 203 ^ Trial 160,^ 242 ^ Trial 173,^ 199 ^ Trial 185^ 230 ^ Trial 191,^ 220 ^ Trial 202,^ 216 ^ Trial 237,^ 198 ^ Trial 241,^ 231 ^ and Trial 278.^ 235 ^ None assessed scarring or long-term morbidity.

#### What Is the Quality of Life (Psychological Morbidity) in Untreated Acne? InTreated Acne?

As described in Chapter 4, only two trials provided specific evidence.

#### What Is the Financial Cost of Therapy?

As described in Chapter 3, no studies provided evidence.

### Limitations

Our conclusions must be qualified because of the great heterogeneity present in the acne literature at all levels: there are a large number of treatments, compared in multiple ways; although there are a limited number of primary acne outcomes, there are a large number of ways of defining on what part of the body lesions are counted (over 30 ways); there are a large number (25) of ways of classifying severity; and there are many ways that these outcomes were expressed (raw measures, absolute change with respect to baseline, and percent change with respect to baseline). There is no standard approach to describing side effects. Similarly, there is no standardization of followup times. Our division into short-term, mid-term, long-term, and post-therapy, while a result of consensus among our technical experts, is still an arbitrary arrangement.

The practical decision to focus on English language reports of trials meant that potentially high quality non-English studies were not included in this review. Syntheses on more focused questions (e.g., a synthesis on isotretinoin alone) should include a search for and inclusion of non-English language reports of trials.

While some effort was made to use sources that may provide nonpublished reports of trials (such as the use of the Cochrane Collaboration's CENTRAL database, which contains hand searching results as well as ongoing trials, and our own searching of reference lists of key articles) we must also recognize that this report is open to publication bias-that is, trials with positive results are more likely to be published, thereby potentially leading to an overestimation of the true effects of the treatments. This report summarizes the available evidence as found in published reports of trials and, as such, may not include all of the relevant evidence. We might expect publication bias in the field of acne, since so much of the research is industry-sponsored, and pharmaceutical companies may be less motivated to publish negative results than researchers without a commercial interest in the results. Syntheses on more focused questions should include a more intensive search for nonpublished reports of trials. This may include a hand search of proceedings of relevant conferences and contacting key researchers in the field to ask if they know of any completed or ongoing unpublished trials.

At the same time, there were some surprises. Some treatments currently in use or soon to be in use had little to no evidence in the literature reviewed. For instance, although tazarotene was recently approved by the FDA for use in acne, we found no published trials in our search procedure that included asking our technical experts for controlled trials we might have missed. (One trial on tazarotene has been published since the literature review for this report was completed.)

Industry plays a major role in acne research. Of the 145 trials (out of 274) that reported funding, 127 were pharmaceutical company funded, and an additional 113 trials mentioned other forms of support from drug companies, such as provision of medicine. Because these companies design their research to comply with FDA requests (in the United States), these requests have a great influence on the nature and scope of the trials on acne. Such requests could encourage pharmaceutical companies to support trials that not only establish the efficacy versus safety of their product but also provide clinicians with the evidence they need to make rational therapeutic decisions.

The heterogeneity of the literature makes it very difficult to pool any results, and, therefore, precludes quantifying the conclusions. We focused on assessing the level of evidence available for any treatment comparison, and we based all assessments of the efficacy of a treatment in terms of comparisons with other treatments, including placebos. Improvements relative to baseline were commonly seen for both active treatments and placebo treatments. This suggests that acne may improve spontaneously and mitigates against drawing conclusions about efficacy from the results of a single arm of a trial, even if large and statistically significant differences were documented with respect to baseline status.

Generally, controlled trials provide limited information on side effects. Readers are cautioned to check other sources for side effect data such as drug inserts.

Finally, the nature of acne itself may be changing. A number of our technical experts expressed concern about bacterial resistance of P acnes, especially to clindamycin and erythromycin. This issue has major consequences for treatment recommendations and for future research.