# APPENDIX G: Article Review Forms

Acne: STUDY ARTICLE ID_________REVIEWER A___________ B________ YEAR: _________ Date

Exclude: Check ANY that apply

Does not discuss acne management | [image]
No human data | [image]
More than 20% of the patients have chloracne, rosacea, venanta, fulminans, necroticans, agminata | [image]
Patients are not baseline normal (e.g., industrial-caused acne) | [image]
Surrogate outcome measures only (e.g., sebum production, P acnes colony counts) | [image]
No original data | [image]
Article not in English | [image]
Fewer than 5 patients | [image]
DO NOT PROCEED FURTHER IF ANY ITEMS CHECKED ABOVE!!!

READ PAPER BEFORE ANSWERING THE FOLLOWING QUESTIONS.............................USE PENCIL!!!!!!

QUESTIONS FOR

PI:(Harold and John)

Experts

STUDY CHARACTERISTICS

1. Design
Treatment was assigned prospectively, randomly or no | Controlled trial | [image]
Group of patients followed prospectively without treatment assignment | Cohort study | [image]
Groups defined as those with or without outcome | Case-control | [image]
One or more groups of patients are examined at one point in time | Cross-sectional | [image]
Data are available on a single group of patients before and after/during the intervention | Before-after | [image]
Single-arm study with more than four patients (note subjectivity) | Case series | [image]
You cannot say based on the information provided | Unspecified | [image]

2. Arms
How many distinct treatment groups were there? | Number of arms | _______

3. Dates
From first patient enrolled to last data collected (xx/19xx or ??? if unclea)r You can enter only the year if that's all you know | Enrollment | ____/_____
xx/19xx or ??? if unclear | End of data collection | ____/_____
If dates aren't given, perhaps the duration is | Study duration | __________
| Units | Wks [image] Mos [image] Yrs [image]

4. Number of sites
Single city/locale | Single | [image]
One country | Multicenter | [image]
Multiple countries | Multicountry | [image]
Not enough data | Can't say | [image]

5. Location
Primary, or coordinating (for multistudy), country of the study | Country | ____________
Primary, or coordinating (for multistudy) state/province of the study | State/Province | __________
Primary, or coordinating (for multistudy) city of the study | City | __________
| Inferred from author address only | [image]

STUDY QUALITY

How did patients get into this study? | | 6. Assembly
All patients who came in through the door were enrolled/included | Consecutive | [image]
Do the authors state the patients were recruited? | Recruited | [image]
| Other | [image]
| Can't say | [image]

What patients were excluded from this study, according to the design description? | | | | | 7. Exclusion criteria
Tanner I | [image] | Female | [image] | Mild acne | [image]
Tanner II | [image] | Male | [image] | Moderate acne | [image]
Tanner III | [image] | | | Severe acne | [image]
Tanner IV | [image] | Asian | [image] | Secondary acne | [image]
Tanner V | [image] | Black | [image]
| | Hispanic | [image] | Pregnancy | [image]
| | Other race | [image] | Lactation | [image]
| | _______________ | | Allergy to study meds | [image]
< 31 days | [image] | White | [image]
31 d to 10 y | [image]
11 y to 14 y | [image] | | | Other comorbid condition | [image]
15 y to 18 y | [image] | | | ____________________ | [image]
19 y to 34 y | [image] | Dry skin | [image]
35 y to 54 y | [image] | Oily skin | [image] | Comedonal acne | [image]
> 54 y | [image] | | | Inflammatory acne | [image]
| | | | Pustular acne | [image]
| | | | Nodularcystic acne | [image]
| | | | None listed | [image]

For what prior treatment regimens were patients excluded? | | 8. Treatment Exclusion criteria
Treatment | Duration | Units
______________________________________ | ___________________ | [image] Days [image] Weeks [image] Months
______________________________________ | ___________________ | [image] Days [image] Weeks [image] Months
______________________________________ | ___________________ | [image] Days [image] Weeks [image] Months
______________________________________ | ___________________ | [image] Days [image] Weeks [image] Months
______________________________________ | ___________________ | [image] Days [image] Weeks [image] Months
| | None listed [image]

| 9. Research design
The standard CCT | Parallel | [image]
With or without initial washout | Cross-over | [image]
There was only one group of patients | Single-arm | [image]
There are not enough data to make a determination | Can't say | [image]

| 9a. Matched control
One or more controlled patient(s) were specified in each experimental patient | Yes | [image]
Design is called matched ,but their are few data or no data to support that | Maybe | [image]
No mention or evidence of matching | No | [image]
| Can't say | [image]

| 10. Research funding
NIH, etc. | Federal | [image]
Drug-company funded, but evaluated in usual peer way | Drug/peer-eval | [image]
Drug-company funded and published in a supplement or worse | Drug/supplement | [image]
There are not enough data to make a determination | Can't say | [image]
E.g., Foundation | Other _______________

How were patients assigned to treatment | 11. Assignment across patients
Based on random numbers, from a table or computer | Randomized | [image]
The authors decoration: call it "randomized," but give no details | Maybe Randomized | [image]
A method that results in assignment that is clearly known in advance, e.g., odds/even clinic days, birthdays, odd/even clinic numbers | Deterministic | [image]
Not enough information to say how assignment was actually made | Can't say | [image]
There were no assignments made to treatment in a prospective manner | Not applicable | [image]

Were different sides of the face (back, etc.) treated differently? | | 12. Assignment within patient
| Split face (or other body part), random | [image]
| Split face (or other) deterministic | [image]
| Can't say | [image]
There was no such assignment made | Not applicable | [image]

Were the patients ignorant about what treatment they got? | 13. Patient blinded
There is clear attempt at documenting whether they knew, and it shows that theydidn't | Yes | [image]
There may be documentation, and it shows that they didn't know, or, from implicit data, you infer that there was fair patient blinding (also if author says "double blind" but no other information provided) | Somewhat | [image]
There is clear attempt at documenting whether they knew, and it shows that they did | No | [image]
There are no implicit or explicit data | Can't say | [image]
| Not applicable | [image]

Was the person enrolling patients ignorant about what treatment would be assigned? This is somewhat dependent on the method of treatment assignment | | 14. Enroller blinded
There is clear attempt at documenting whether they were ignorant, and it shows that they were ignorant | Yes | [image]
Either the method (based on your background knowledge) or the data suggest that there was some unblinded enrollment (also if author says "double blinded" but no other information provided) | Somewhat | [image]
The method or the data make it clear that enrollers knew the prospective enrollment | No | [image]
There are no implicit or explicit data | Can't say | [image]
There was no assignment made | Not applicable | [image]

Was compliance of the patients to their assigned treatment monitored? | | 15. Compliance monitoring
Monitoring was planned from the outset and was followed | Prospectively | [image]
Although not planned, there are data about compliance | Retrospectively | [image]
There was a plan for monitoring, but the results are not reported or no plan and no data reported | Maybe | [image]
Neither explicit (e.g., survey) nor implicit (e.g., side effect rates) data are available to make this assessment | Can't say | [image]
There was no assignment made | Not applicable | [image]

What part(s) of the body was treated? | | 16. Body area
| Face | [image]
| Chest | [image]
| Back | [image]
| Systemic | [image]
| | [image]
Other

What was the nature of the medical care that patients received in ALL arms? | | 17. Type of care
Community office | Clinic visits | [image]
Includes academic clinic | Hospital visits | [image]
| Home | [image]
Other
________________________________________
| Can't say | [image]

What was the nature of the things excluded from ALL arms? | | 18. Ancillary Rx: Excluded Rx
| Medication | [image]
| Soaps | [image]
| Diet | [image]
Other | | [image]
| ___________________________________________
| Can't say | [image]

Was ancillary treatment similar across arms? | | 19. Equal ancillary Rx across arms
| Yes | [image]
Some doubt about the consistency, based on data or your background knowledge | Maybe | [image]
Clearly differences in ancillary treatment that are important | No | [image]
There are not enough data to determine | Can't say | [image]
There was no assignment made | Not applicable | [image]

"LTFU" includes any patient for whom (primary) outcome data are NOT available | | 20. Losses to follow-up
The number of patients LFTU comprise less than 5% of the sample, and were evenly distributed across arms | None | [image]
LTFU comprises between 5 and 20%, evenly distributed | Minor | [image]
LTFU comprise greater than 20% or grossly asymmetric | Major | [image]
There are no data on LTFU | Can't say | [image]
This was a retrospective study | Not applicable | [image]

"PD" includes dropouts, withdrawals, and unintended cross-overs for whom outcome data ARE available
21. Protocol departures
The number of PD comprise less than 5% of the sample, were evenly distributed across arms, and outcome data are available on any that did depart. | None | [image]
PD comprises between 5% and 20%, are evenly distributed, and outcome data are 80% known. | Minor | [image]
PD comprises greater than 20% or what PD there is unaccounted for or outcome data are not known and could subvert the study's conclusion so | Major | [image]
There are no data on protocol departures | Can't say | [image]
There was no protocol | Not applicable | [image]

Was the process by which patient came to have their outcomes assessed consistent across arm? Examples of not consistent would be inpatients vs outpatients or other more subtle differences
22. Ascertainment consistent across arms
No doubt about the consistency | Yes | [image]
Some doubt about the consistency | Maybe | [image]
Clearly differences in ascertainment | No | [image]
There are not enough data to determine | Can't say | [image]
There was no assignment made | Not applicable | [image]

Were the person/people assessing the outcomes blinded to assignment? These may be the same as the treaters. If there was blinding for some outcomes, but not for others, list here the best level of blinding, and make a Comment about the worse level on the data table about that outcom (in ARM form)
23. Outcomes assessor blinded
Totally blinded | Yes | [image]
Some degree of blinding, but the lack of blinding is unimportant (also if author says "double blinded" but no other information provided) | Somewhat | [image]
Clearly differences in ascertainment | No | [image]
There are not enough data to determine | Can't say | [image]
There was only one arm | Not applicable | [image]

Based on your judgment, paying attention especially to "Table 1," the table of baseline characteristics of the patients in each arm. If a couple of characteristics are statistically significantly different between the groups, they may still be comparable if those characteristics are unimportant.
24. Comparability of the arms.
Many important characteristics were assessed, and they are equally represented in the different arms | Yes | [image]
Some important characteristics were not assessed, or at most one or two of those characteristics that were assessed are different among the groups, but probably not important | Maybe | [image]
Several characteristics are different, and they are important | No | [image]
There are not enough data about the execution to permit a conclusion | Can't say | [image]
There is only one arm in this study | Not applicable | [image]

Based upon your judgment. This judgment synthesizes what you've read
25. Execution true to study design
The execution followed the design, and any problems you detected do not detract from inferences assuming that that study was performed ideally | Yes | [image]
The execution essentially followed the design, but some departures from design may invalidate the results | Somewhat | [image]
The study as executed is different enough from design that inferences are called fundamentally into question | No | [image]
There are not enough data about the execution to permit a conclusion | Can't say | [image]

What is the most general group of patient for which this study's results are valid, in your opinion, taking the design and results into account
26. Generalizability
E.g., all peoples | General population | [image]
E.g., all white 14-year olds | Specific population | [image]
E.g., all white 14 olds in Baltimore | Local population | [image]
E.g., all patient referred to a specialty clinic | Referral population | [image]
E.g., patients in the study only, because selection bias or other issues prevents generalizability | Study patients | [image]
There are not enough data about the execution to permit a conclusion | Can't say | [image]

SECONDARY REVIEWER ONLY!!! | 27. Number of Disagreements
Compare your review with the primary review. Include all study areas(i.e,on green form only) where your changes made substantive changes. Addenda, misspelling, etc., are not included in this assessment | Number | _________

Please enter one sentence summary of the conclusions of the study. | 28. Bottom line
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________

Please add any additional information you think a reader of the evidence report would like to know about this study. | 29. Comments
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________
_______________________________________________________________________

ARM NAME: (Prefer use treatment name here)

1.Generic name
2.Type | Med [image] Surg [image] Altern [image] | Med [image] Surg [image] Altern [image] | Med [image] Surg [image] Altern [image]
3.Avalability (in 1999) | OTC [image] Rx [image] Study [image] | OTC [image] Rx [image] Study [image] | OTC [image] Rx [image] Study [image]
4.Brand name
5.Route | Topical [image] po [image] Other [image] Specify (if other) | Topical [image] po [image] Other [image] Specify (if other) | Topical [image] po [image] Other [image] Specify (if other)
6.Vehicle | ConstituentPercent _______________ ____________ __________ Can't say [image] | ConstituentPercent _______________ ____________ __________ Can't say [image] | ConstituentPercent _______________ ____________ __________ Can't say [image]
7.Dose | Can't say [image] | Can't say [image] | Can't say [image]
8.Units(e.g., mg/kg)
9.Frequency (e.g., tid) | qd [image] bid [image] tid [image] qid [image] qhs [image] other | qd [image] bid [image] tid [image] qid [image] qhs [image] other | qd [image] bid [image] tid [image] qid [image] qhs [image] other
10.Compliance (if monitored). | >80% [image] 50-80% [image] <50% [image] Can't say [image] | >80% [image] 50-80% [image] <50% [image] Can't say [image] ........................ | >80% [image] 50-80% [image] <50% [image] Can't say [image] ........................

11.Ancillary treatment
12.Comments

  PATIENT CHARACTERISTICS FOR
  ARM | [image]
  ENTIRE STUDY | [image]
  (Use "Entire Study" only if no arm-specific data are available)

For each characteristic, enter the NUMBER of patients with that characteristic (often seen in "Table 1")

Intent to treat is preferred | 1. Source of data
Characteristics of patient as they entered the study | Intent to treat | [image]
Characteristics of patients during the study | Interim | [image]
Characteristics of the patients left at the end of the study | Terminal | [image]
| Can't say | [image]

2. Tanner stage (# pts)
Tanner I ____________
Tanner II____________
Tanner III____________
Tanner IV____________
Tanner V____________
Unspecified [image]

3. Age (#pts.)
< 31 days__________
31 d to 10 y _________
11 y to 14 y__________
15 y to 18 y__________
15 y to 18 y__________
19 y to 22 y__________
23 y to 26 y__________
27 y to 34 y__________
35 y to 54 y__________
> 54 y__________
__________________________________
Or, if there is no breakdown.. Mean (yrs)_________
Standard Deviation (yrs)_________
Range (yrs)_________ to_________
Can't say [image]

4. Sex (#pts.)
Female __________
Male __________
Can't say [image]

5. Race (#pts.)
Asian __________
Black __________
Hispanic __________
White __________
Other_______________ __________
Can't say [image]

6.Skin Type(#pts.)
Dry ___________
Oily __________
Normal __________
Can't say [image]

7.Diet (#pts.)
Was this group constituted on the basis of diet, or did they share a similar diet? | Diet_______________ __________
No, or there are no data | Can't say [image]

8. Disease duration
9. Acne severity (# pts.)
| Mean | SD | Units
What was the mean and SD of the duration of disease before patients came to treatment in this study; include time of prior treatment Include units (years, months..). If there are no data on disease duration, check this radio button. | __________ | __________ | _______________
| | Can't say | [image]
| | Mild | __________
| Moderate | __________
| Moderately severe | __________
| Severe | __________
Other______________________________________________ | | __________
Other______________________________________________ | | __________
Other______________________________________________ | | __________
Can't say | | __________
Mean | | __________
SD | | __________
| | # Lesions, type [image]
Indicate the WAY that acne severity was assessed (include brief citation, if available). Select "subjective" if only "mild," etc, used without a formal citation | Method of assessment | Subjective [image] Other [image] ___________
Citation
______________________________________________

10. Insurance (#pts.)
Fee for service __________
Capitation __________
None __________
Can't say [image]
Even if patients said they had insurance, does their coverage include the drugs OF THIS STUDY

11. Prescription plan (#pts.)
Yes __________
No __________
Can't say [image]

Number of lesions per patient | | | 12. Acne Type
| | Mean | SD | Range
| Open Comedones
| Close Comedones
Non-inflammatory | Total Commedones
Non-inflammatory | Other non-Inflammatory
Non-inflammatory | Total Non-Inflammatory
| Papules
Inflammatory | Pustules
Inflammatory | Other Inflammatory
Inflammatory | Total Inflammatory
| Mixed Inflammatory/non-inflammatory
| Nodules
Nodulocystic | Cysts
Nodulocystic | Nodulocysts
Other______________________
If another way of describing acne type was used, write the method here (along with a citation, if available) | Can't say | [image]
Citation ______________
Citation ______________ | | Method of assessment____________________________________
_________________________________________________________________________
Self ___________
Generalist ___________
Dermatologist ___________
Study clinic ___________
Can't say [image]

If a multicenter site, use the majority type of practice setting) 14. Practice Setting (#pts.)
Self ___________
Private practice ___________
College/school health clinic ___________
Staff HMO ___________
Study site ___________
Hospital ___________
Can't say [image]

At start of study, the patients were at what-15. Phase of Care (#pts.)
Before first MD visit ___________
After initial MD care ___________
After follow-up visit ___________
After further care ___________
After referral ___________
Can't say [image]

| COMMENTS
__________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________ __________________________________________________________________________________

CONTINUOUS OUTCOME NAME:

ONE PAGE FOR EACH OUTCOME. For a single outcome with multiple times, use SEPARATE PAGES for each time.

1. Outcome Type | Acne [image] | Psychological [image] | Adverse effect [image]
1. Outcome Type | Economic [image] | Compliance [image]
2. Outcome Definition Operational definition as defined in the study, e.g., how was lesion severity assessed; what instrument was used?
3. Outcome Definition Citation
4. Objectivity of assessment In your judgment, was the method of assessment objective or not (subjective) | Yes [image] | | No [image]
4. Objectivity of assessment In your judgment, was the method of assessment objective or not (subjective) | Somewhat [image] "Somewhat" = Although subjective, assessment was systematic | | Can't say [image]
5. Consistency of assessment Was the assessment made the same way in all patients in this arm? | Yes [image] | | No [image]
5. Consistency of assessment Was the assessment made the same way in all patients in this arm? | Somewhat [image] | | Can't say [image]
6. Denominator USED BY AUTHOR FOR STUDY where denominator for each arm not available | | | Can't say [image]

ARM (Treatment Name)
1. Denominator by ITT Intention to treat | Can't say [image] | Can't say [image] | Can't say [image]
2. Denominator used by author/ | Can't say [image] | Can't say [image] | Can't say [image]
2a. Number lost to follow-up | Can't say [image] | Can't say [image] | Can't say [image]
3. Outcome Mean
4. Outcome SD
5. Follow up duration, mean
6. Follow up duration, standard deviation | Can't say [image] | Can't say [image] | Can't say [image]
7. Follow up duration, units
8. Raw data cannot be reconstructed | [image] | [image] | [image]

(std dev = std error * sqrt(arm size)

9. Data source (Page #/Table #)
10. Comments (over if necessary)

DISCRETE OUTCOME NAME:

1. Outcome Type | Acne [image] | Psychological [image] | Adverse effect [image]
1. Outcome Type | Economic [image] | Compliance [image]
2. Outcome Definition Operational definition as defined in the study, e.g., how was lesion severity assessed; what instrument was used?
3. Outcome Definition Citation
4. Objectivity of assessment In your judgment, was the method of assessment objective or not (subjective) | Yes [image] | | No [image]
4. Objectivity of assessment In your judgment, was the method of assessment objective or not (subjective) | Somewhat [image] "Somewhat" = Although subjective, assessment was systematic | | Can't say [image]
5. Consistency of assessment Was the assessment made the same way in all patients in this arm? | Yes [image] | | No [image]
5. Consistency of assessment Was the assessment made the same way in all patients in this arm? | Somewhat [image] | | Can't say [image]
6. Denominator USED BY AUTHOR FOR STUDY where denominator for each arm not available | Can't say

ARM (Treatment Name)
1. Denominator by ITT Intention to treat | | Can't say [image] | Can't say [image] | Can't say [image]
2. Denominator used by author/ | | Can't say [image] | Can't say [image] | Can't say [image]
2a. Number lost to follow-up | | Can't say [image] | Can't say [image] | Can't say [image]
3. Numerators | Labels
Category 1
Category 2
Category 3
Category 4
Category 5
Category 6
Category 7
Category 8
4. Follow up duration, mean
5. Follow up duration, standard deviation | | Can't say [image] | Can't say [image] | Can't say [image]
6. Follow up duration, units Preference 6 & 12 weeks
7. Raw data cannot be reconstructed | | [image] | [image] | [image]

std dev = std error * sqrt(arm size)

9. Data source (Page #/Table #)
10. Comments (over if necessary)