# Appendix F: Abstract Form

Acne Abstract Review Form

Reviewer: _________

Entered: __________

Delete, because article (check one): | Study areas addressed (check all that apply):
[image] did not address management of acne [image] did not include human data [image] only addressed chloracne, acne rosacea, acne venanta, acne fulminans, acne necroticans, acne agminata [image] no original data [image] article not in English Specify language:__________________ Do not go on if any of above are checked Type of evidence: [image] controlled trial [image] cohort study [image] case-control study [image] case-series/case-report [image] review [image] opinion/editorial [image] unclear | [image] Medical outcomes [image] Treatment [image] Cost [image] Psychological morbidities [image] Acne severity [image] Acne type [image] Patient characteristics [image] Source of care [image] None of the above [image] None of the above, but relevant to: ___________________________________________ [image] Unclear, retrieve article Comments: ________________________________________________ ________________________________________________