# Appendix E: Search Strategies

CENTRAL Core Search Strategy

1 acne-vulgaris*.me
2 acne*.tw
3 #1 or #2

PubMed Core Strategy

(((randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized controlled trials [mh] OR random allocation [mh] OR double-blind method [mh] OR single-blind method [mh] OR clinical trial [pt] OR clinical trials [mh] OR (clinic* [tw] AND trial* [tw]) OR ((singl* [tw] OR doubl* [tw] OR trebl* [tw] OR tripl* [tw]) AND (mask* [tw] OR blind* [tw])) OR (latin [tw] AND square [tw]) OR placebos [mh] OR placebo* [tw] OR random* [tw] OR research design [mh:noexp]) NOT (animal [mh] NOT human [mh]))) AND (acne vulgaris[mh] OR acne*[tw])

OLDMEDLINE Core Search Strategy

acne vulgaris (kw) OR (acne (tw) and vulgaris (tw))

OLDMEDLINE Text Search Strategy

acne (kw) OR acne (tw)

CINAHL^®^ Core Search Strategy

Acne/or acne vulgaris.ti,sh,ab,it

PsycINFO^®^ Core Search Strategy

acne vulgaris [words anywhere] OR acne [words anywhere]

Supplemental Search Strategy: Cost

(acne vulgaris [mh] OR acne [tw]) AND ("economics"[Subheading] OR "financial management"[mh] OR "economics"[mh] OR economics[tw] or "costs and cost analysis"[mh] OR cost*[tw])