# Appendix D: Study Questions: Expert Feedback

January 25, 1999 | Management of Acne AHCPR Evidence Report | FAX to: 410-614-9878

Feedback Regarding Study Questions and Exclusions

Feedback from: | ______________________________________________________
| First Name | Last Name
Date: | _______________________
Number of pages (including this one): _______
_____________________________________________________________________________

Study Questions:

We have enclosed the study questions for this project. These questions were developed based upon a preliminary review of the evidence and feedback from our Partners and Technical Experts. Please provide comments regarding the study questions by writing on and faxing back the page(s) with the questions and/or provide comments here:

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

Exclusions:

As outlined in deliverable 5a (enclosed), our literature search and review will be guided by the study questions, and by inclusion and exclusion criteria. We would like your confirmation that we have made appropriate decisions, based upon previous feedback and the preliminary review, regarding the exclusion criteria we have set.

1. In general, we feel that it is beyond the scope of this evidence report to examine endocrinopathies; to do so would necessitate an examination of underlying medical conditions. Do you agree that this report should focus on the management of acne in patients whose exam and medical condition is otherwise normal? (circle one) Yes No Comments: __________________________________________________
2. We have set specific exclusions and include these below.

Please place a check beside those you agree shouldbeexcluded from this report:

[image] chloracne | [image] acne rosacea
[image] acne venanta | [image] acne fulminans
[image] acne necroticans | [image] acne agminata
Others? Please specify:
[image]_________________________ | [image]_________________________

Notes for study questions:

1. Outcomes: Outcomes of interest include acne residual, quality of life, cost and other morbidities. Sequelae of acne (acne residual) include scarring and hyperpigmentation.
2. Treatment: Includes the following:
  I. Pharmaceutical interventions:
    i. FDA approved prescription drugs
    ii. FDA approved OTC
    iii. Alternative therapies
    iv. Pharmaceutical treatments used outside of the United States
  II. Surgical interventions
3. Patient Age: We will include all ages in our search. Where possible, we will stratify by age. For instance, based on the preliminary literature review, we may stratify Tanner Stage V by age (adolescents, young adults and older adults).
4. Acne Severity
5. Acne Type
6. Patient Characteristics: We have listed in the question, patient characteristics that appear to have an influence on the management of acne. Insurance status of an individual may be MCO, fee-for-service, no insurance and public assistance.
7. Source of care: Includes issue of variation of practice.
8. Population outcomes