# Appendix C: Study Questions

## Management of Acne-AHCPR Evidence ReportStudy Questions

Question 1

What is the effect on | acne sequelae of acne costs psychological effects adverse effects 1 | of | treatment 2 | in | children adolescents young adults older adults 3 | with
mild moderate severe 4 | nodulocystic comedonal pustular 5 | acne, and with | race skin type duration of disease diet geographic environment insurance status 6 | , who are treated by | self generalist dermatologist 7 | ?

Question 2

What are the | economic costs physical effects psychological effects 8 | of acne and its sequelae in a population?