# Appendix B: Study Questions: Refinement by Experts

## Regarding the AHCPR ACNE PROJECT

Dear <<Technical Advisor>>,

A major responsibility in this project is to help us refine the topics and questions for evidence review. Please complete this questionnaire. Feel free to call or email us with questions. There are strict time constraints from the AHCPR. We need a RAPID response. Please FAX your responses by DEC 18 (410 614-9878).

1. Below is a non-prioritorized list of questions elicited from experts, professional organizations, and consumers. For each question, please - Rate the Importance to your constituency of the questions, from 1 (Unimportant) to 10 (Vitally Important). - Rate your sense of the Data Availability to answer the questions, from 1 (Unavailable) to 10 (Available through a simple Medline query). - Provide some Comments, giving a sense of what you think the answer will be, or how established the answer might already be.

Question | Importance | Data Availability | Comments
Are there predictors of acne severity (race, time with acne, history of treatment, diet, hygiene)?
Does acne treatment effectiveness vary by severity/type of acne?
To what extent does health insurance cover acne treatment?
At what point do patients seek, or want to seek, medical care?
How do generalists and specialists compare in their ability to diagnose acne and its severity?
What is the effectiveness of OTC preparations and their combinations in treating acne?
What is the efficacy of FDA-approved drugs for treating acne, and the efficacy of their combinations?
What is the efficacy of treatments not FDA approved in treating acne?
What is the efficacy of treatments used outside the United States in treating acne?
What treatments are known not to be effective in treating acne?
How do generalists and specialists differ in their manageent (appropriate or otherwise) of acne?
What should be the first-line, second-line, and third-line treatments for acne?
Does response to second-line therapy depend on prior length of time with acne and response to first-line treatment?
At what point in the treatment process should men receive isoretinoin (Accutane)?
At what point in the treatment process should women receive isoretinoin (Accutane)?
At what point in the treatment process should a patient be referred to a dermatologist?
What are the frequencies of side effects of treatment?
Does the type of acne remain constant within an individual?
To what extent does antibiotic resistance develop in patients treated with oral or topical antibiotics for acne?
What are patient preferences regarding acne treatment?
How cost-effective are different acne treatment strategies?
How should patients with acne be treated in whom isoretinoin (Accutane) fails?
How should post-treatment scarring and hyperpigmentation be treated?

2. Please write any further questions, their importance, data availability, and sense of the answer:

______________________________________________________________________________

______________________________________________________________________________

______________________________________________________________________________

3. We will be searching MEDLINE, COCHRANE, HEALTHSTAR, and PSYCHINFO. Do you have any further suggestions for searching?

______________________________________________________________________________

______________________________________________________________________________

4. How would you or your group use the evidence report? Please check all that apply.

___ For internal guideline

___ For collaborative guideline with other organizations

___ Disseminating management plan

___ Other (please specify) ________________________________________________________

___ Other (please specify) ________________________________________________________

___ Other (please specify) ________________________________________________________

5. Complete by (Name, phone, fax, and email, if we don't already have them):

_____________________________________________________________________________

_____________________________________________________________________________