# Appendix A: Technical Experts and Peer Reviewers

## Technical Experts

- Nancy Barnett
- Johns Hopkins Evidence-based Practice Center

- Bob Bryant
- American Pharmaceutical Association

- Mary-Margaret Chren
- American Academy of Dermatology

- Tsu-Yi Chuang
- American Academy of Dermatology

- Bernard Cohen
- Johns Hopkins Evidence-based Practice Center

- Anne Eady
- Skin Collaborative Review Group, Cochrane Collaboration

- Evan R. Farmer
- American Academy of Dermatology

- James Herbert
- American Academy of Pediatrics/Committee on Practice and Ambulatory Medicine

- Alain Joffe
- Johns Hopkins Evidence-based Practice Center

- Daniel Krowchuk
- American Academy of Pediatrics

- Anne W. Lucky
- American Academy of Dermatology

- Gary Peck
- American Academy of Dermatology

- John Strauss
- Society for Investigational Dermatology
- American Academy of Dermatology

## Peer Reviewers

- Pat Alguire
- Society for General Internal Medicne

- Martin Fisher
- Society for Adolescent Medicine

- Kathleen C. Teets Grimm
- American Academy of Pediatrics/Committee on Practice and Ambulatory Medicine

- Martin Mahoney
- American Academy of Family Practitioners

- Alan Moshell
- National Institute of Arthritis, Musculoskeletal, and Skin Diseases

- Alan R. Shalita
- American Academy of Dermatology

- Diane Thiboutot
- Society for Investigative Dermatology

- Jonathan D.K. Trager
- Society for Adolescent Medicine

- Barbara Yawn
- American Academy of Family Practitioners