# Appendixes

Appendix A: Technical Experts and Peer Reviewers

Appendix B: Study Questions: Refinement by Experts

Appendix C: Study Questions

Appendix D: Study Questions: Expert Feedback

Appendix E: Search Strategies

Appendix F: Abstract Form

APPENDIX G: Article Review Forms