# References

1 Flegal KM, Carroll MD, Ogden CL, et al. Prevalence and trends in obesity among US adults, 1999-2000. JAMA. 2002;288(14):1723-7. [pmid: 12365955].
2 Mokdad AH, Bowman BA, Ford ES, et al. The continuing epidemics of obesity and diabetes in the United States. JAMA. 2001;286(10):1195-200. [pmid: 11559264].
3 Mokdad AH, Serdula MK, Dietz WH, et al. The continuing epidemic of obesity in the United States. JAMA. 2000;284(13):1650-1. [pmid: 11015792].
4 Mokdad AH, Serdula MK, Dietz WH, et al. The spread of the obesity epidemic in the United States, 1991-1998. JAMA. 1999;282(16):1519-22. [pmid: 10546690].
5 Centers for Disease Control and Prevention. Obesity epidemic increases dramatically in the United States. available at URL: http://www.cdc.gov/nccdphp/dnpa/obesityepidemichim. Accessed 6/11/2002.
6 Kuczmarski RJ, Flegal KM, Campbell SM, et al. Increasing prevalence of overweight among US adults. The National Health and Nutrition Examination Surveys, 1960 to 1991. JAMA. 1994;272(3):205-11. [pmid: 8022039].
7 Katzmarzyk PT. The Canadian obesity epidemic, 1985-1998. CMAJ. 2002;166(8):1039-40. [pmid: 12002980]. [pmcid: 100878].
8 Katzmarzyk PT. Obesity in Canadian children. CMAJ. 2001;164(11):1563-4. ; author reply 1564–5. [pmid: 11402790].
9 World Health Organization. Controlling the global obesity epidemic. available at URL: http://www.who.int/nut/obs.html. Accessed 6/20/2002.
10 Friedrich MJ. Epidemic of obesity expands its spread to developing countries. JAMA. 2002;287(11):1382-6. [pmid: 11903011].
11 Must A, Spadano J, Coakley EH, et al. The disease burden associated with overweight and obesity. JAMA. 1999;282(16):1523-9. [pmid: 10546691].
12 Pi-Sunyer FX. Medical hazards of obesity. Ann Intern Med. 1993;119(7 Pt 2):655-60. [pmid: 8363192].
13 Sturm R. Increases in morbid obesity in the USA: 2000-2005. Public Health. 2007;121(7):492-6. [pmid: 17399752].
14 Clinical Guidelines on the Identification, Evaluation, and Treatment of Overweight and Obesity in Adults—The Evidence Report. National Institutes of Health. Obes Res 1998;6 Suppl 2:51S–209S.
15 Pi-Sunyer FX. A review of long-term studies evaluating the efficacy of weight loss in ameliorating disorders associated with obesity. Clin Ther. 1996;18(6):1006-35. discussion 1005. [pmid: 9001821].
16 Allison DB, Pi-Sunyer FX. Obesity treatment: examining the premises. Endocr Pract. 1995;1(5):353-64. [pmid: 15251583].
17 Sjostrom L, Lindroos AK, Peltonen M, et al. Lifestyle, diabetes, and cardiovascular risk factors 10 years after bariatric surgery. N Engl J Med. 2004;351(26):2683-93. [pmid: 15616203].
18 Li Z, Maglione M, Tu W, et al. Meta-analysis: pharmacologic treatment of obesity. Ann Intern Med. 2005;142(7):532-46. [pmid: 15809465].
19 Gardner CD, Kiazand A, Alhassan S, et al. Comparison of the Atkins, Zone, Ornish, and LEARN diets for change in weight and related risk factors among overweight premenopausal women: the A TO Z Weight Loss Study: a randomized trial. JAMA. 2007;297(9):969-77. [pmid: 17341711].
20 Maggard MA, Shugarman LR, Suttorp M, et al. Meta-analysis: surgical treatment of obesity. Ann Intern Med. 2005;142(7):547-59. [pmid: 15809466].
21 American Society of Bariatric and Metabolic Surgery. available at URL: http://www.asbs.org/html/patients/bypass.htm. Accessed 7/12/2007.
22 Shauer P. Presidential address. ASBS Annual Meeting; San Diego, CA. 6 June 2007.
23 Santry HP, Gillen DL, Lauderdale DS. Trends in bariatric surgical procedures. JAMA. 2005;294(15):1909-17. [pmid: 16234497].
24 Agency of Healthcare Research and Quality. HCUP Nationwide Inpatient Sample (NIS). Rockville, MD: 2000-2001.
25 SAS Software [computer program]. Version 9.1. Cary, NC: SAS Institute Inc.; 2004.
26 Zhao Y, Encinosa W. Statistical Brief#23: Bariatric Surgery Utilization and Outcomes in 1998 and 2004. available at URL: http://www.hcup-us.ahrq.gov/reports/statbriefs/sb23.jsp. Accessed 10/10/2007.
27 Deitel M, Stone E, Kassam HA, et al. Gynecologic-obstetric changes after loss of massive excess weight following bariatric surgery. J Am Coll Nutr. 1988;7(2):147-53. [pmid: 3361039].
28 Bilenka B, Ben-Shlomo I, Cozacov C, et al. Fertility, miscarriage and pregnancy after vertical banded gastroplasty operation for morbid obesity. Acta Obstet Gynecol Scand. 1995;74(1):42-4. [pmid: 7856431].
29 Marceau P, Kaufman D, Biron S, et al. Outcome of pregnancies after biliopancreatic diversion. Obes Surg. 2004;14 (3):318-24. [pmid: 15072650].
30 Sheiner E, Levy A, Silverberg D, et al. Pregnancy after bariatric surgery is not associated with adverse perinatal outcome. Am J Obstet Gynecol. 2004;190(5):1335-40. [pmid: 15167839].
31 Sheiner E, Menes TS, Silverberg D, et al. Pregnancy outcome of patients with gestational diabetes mellitus following bariatric surgery. Am J Obstet Gynecol. 2006;194(2):431-5. [pmid: 16458641].
32 Hall JC, Watts JM, O'Brien PE, et al. Gastric surgery for morbid obesity. The Adelaide Study. Ann Surg. 1990;211(4):419-27. [pmid: 2181950]. [pmcid: 1358027].
33 Dixon JB, Dixon ME, O'Brien PE. Pregnancy after Lap-Band surgery: management of the band to achieve healthy weight outcomes. Obes Surg. 2001;11(1):59-65. [pmid: 11361170].
34 Martin LF, Finigan KM, Nolan TE. Pregnancy after adjustable gastric banding. Obstet Gynecol. 2000;95(6 Pt 1):927-30. [pmid: 10831994].
35 Friedman D, Semino G, Gianetta E, et al. Aspects of pregnancy following biliopancreatic diversion. Int J Obes. 1989;13:599.
36 Weiner R, Blanco-Engert R, Weiner S, et al. Outcome after laparoscopic adjustable gastric banding - 8 years experience. Obes Surg. 2003;13(3):427-34. [pmid: 12841906].
37 Wittgrove AC, Jester L, Wittgrove P, et al. Pregnancy following gastric bypass for morbid obesity. Obes Surg. 1998;8(4):461-4. discussion 465–6. [pmid: 9731683].
38 Gerrits EG, Ceulemans R, van Hee R, et al. Contraceptive treatment after biliopancreatic diversion needs consensus. Obes Surg. 2003;13(3):378-82. [pmid: 12841897].
39 Eid GM, Cottam DR, Velcu LM, et al. Effective treatment of polycystic ovarian syndrome with Roux-en-Y gastric bypass. Surg Obes Relat Dis. 2005;1(2):77-80. [pmid: 16925218].
40 In: Hatcher RA, Trussell J, Stewart F, Stewart GK, Kowal D., et al. Contraceptive Technology. New York: Irvington Publishers; 1994. p. 113.
41 Tucker ON, Szomstein S, Rosenthal RJ. Nutritional consequences of weight-loss surgery. Med Clin North Am 2007;91(3):499–514, xii.
42 Parkes E. Nutritional management of patients after bariatric surgery. Am J Med Sci. 2006;331(4):207-13. [pmid: 16617236].
43 Dixon JB, Dixon ME, O'Brien PE. Birth outcomes in obese women after laparoscopic adjustable gastric banding. Obstet Gynecol. 2005;106(5 Pt 1):965-72. [pmid: 16260513].
44 Printen KJ, Scott D. Pregnancy following gastric bypass for the treatment of morbid obesity. Am Surg. 1982;48(8):363-5. [pmid: 7114602].
45 Dao T, Kuhn J, Ehmer D, et al. Pregnancy outcomes after gastric-bypass surgery. Am J Surg. 2006;192(6):762-6. [pmid: 17161090].
46 Adami GF, Friedman D, Cuneo S, et al. Intravenous nutritional support in pregnancy. Experience following biliopancreatic diversion. Clin Nutr. 1992;11(2):106-9. [pmid: 16839982].
47 Friedman D, Cuneo S, Valenzano M, et al. Pregnancies in an 18-Year Follow-up after Biliopancreatic Diversion. Obes Surg. 1995;5(3):308-313. [pmid: 10733817].
48 Cools M, Duval EL, Jespers A. Adverse neonatal outcome after maternal biliopancreatic diversion operation: report of nine cases. Eur J Pediatr. 2006;165(3):199-202. [pmid: 16416132].
49 St George LI, Lin D. Malabsorption in pregnancy after biliopancreatic diversion for morbid obesity. Med J Aust. 2005;182(6):308-9. [pmid: 15777149].
50 Smets KJ, Barlow T, Vanhaesebrouck P. Maternal vitamin A deficiency and neonatal microphthalmia: complications of biliopancreatic diversion?. Eur J Pediatr. 2006;165(7):502-4. [pmid: 16718478].
51 Huerta S, Rogers LM, Li Z, et al. Vitamin A deficiency in a newborn resulting from maternal hypovitaminosis A after biliopancreatic diversion for the treatment of morbid obesity. Am J Clin Nutr. 2002;76(2):426-9. [pmid: 12145017].
52 Martin L, Chavez GF, Adams MJ Jr, et al. Gastric bypass surgery as maternal risk factor for neural tube defects. Lancet. 1988;1(8586):640-1. [pmid: 2894563].
53 Haddow JE, Hill LE, Kloza EM, et al. Neural tube defects after gastric bypass. Lancet. 1986;1(8493):1330. [pmid: 2872457].
54 Campbell CD, Ganesh J, Ficicioglu C. Two newborns with nutritional vitamin B12 deficiency: challenges in newborn screening for vitamin B12 deficiency. Haematologica. 2005;90(12 Suppl):ECR45. [pmid: 15642668].
55 Martens WS 2nd, Martin LF, Berlin CM Jr. Failure of a nursing infant to thrive after the mother's gastric bypass for morbid obesity. Pediatrics. 1990;86(5):777-8. [pmid: 2235232].
56 Grange DK, Finlay JL. Nutritional vitamin B12 deficiency in a breastfed infant following maternal gastric bypass. Pediatr Hematol Oncol. 1994;11(3):311-8. [pmid: 8060815].
57 Gurewitsch ED, Smith-Levitin M, Mack J. Pregnancy following gastric bypass surgery for morbid obesity. Obstet Gynecol. 1996;88(4 Pt 2):658-61. [pmid: 8841242].
58 Weiss HG, Nehoda H, Labeck B, et al. Pregnancies after adjustable gastric banding. Obes Surg. 2001;11(3):303-6. [pmid: 11433905].
59 Gaudry P, Maurice A, Montagliani L, et al. [Pregnancy after adjustable gastric band for morbid obesity: specific features of follow-up]. J Gynecol Obstet Biol Reprod (Paris). 2004;33(3):235-40. [pmid: 15170438].
60 Skull AJ, Slater GH, Duncombe JE, et al. Laparoscopic adjustable banding in pregnancy: safety, patient tolerance and effect on obesity-related pregnancy outcomes. Obes Surg. 2004;14(2):230-5. [pmid: 15018752].
61 Martin LF, Finigan KM, Rabner JG, et al. Adjustable gastric banding and pregnancy. Obesity Surgery. 1997;7(4):280-281.
62 Bar-Zohar D, Azem F, Klausner J, et al. Pregnancy after laparoscopic adjustable gastric banding: perinatal outcome is favorable also for women with relatively high gestational weight gain. Surg Endosc. 2006;20(10):1580-3. [pmid: 16902748].
63 Rand CS, Macgregor AM. Medical care and pregnancy outcome after gastric bypass surgery for obesity. South Med J. 1989;82(10):1319-20. [pmid: 2799456].
64 Biron S, Hould F, Simard S. Birthweight after biliopancreatic diversion. Obes Surg. 1999;9:126.
65 Chapman R, Chapman K. Pregnancy occurring in a morbidly obese woman who had undergone gastric stapling. J R Soc Med. 1991;84(8):503-4. [pmid: 1886126]. [pmcid: 1293389].
66 Granstrom L, Granstrom L, Backman L. Fetal growth retardation after gastric banding. Acta Obstet Gynecol Scand. 1990;69(6):533-6. [pmid: 2126658].
67 Richards DS, Miller DK, Goodman GN. Pregnancy after gastric bypass for morbid obesity. J Reprod Med. 1987;32(3):172-6. [pmid: 3572896].
68 Jester L, Wittgrove AC, Clark GW. Evaluation of pregnancy after bariatric surgery and a developmental study of the children over two years of age. Obesity Surgery. 1997;7(4):280.
69 Strauss RS, Bradley LJ, Brolin RE. Gastric bypass surgery in adolescents with morbid obesity. J Pediatr. 2001;138(4):499-504. [pmid: 11295712].
70 Kral JG, Biron S, Simard S, et al. Large maternal weight loss from obesity surgery prevents transmission of obesity to children who were followed for 2 to 18 years. Pediatrics. 2006;118(6):e1644-9. [pmid: 17142494].
71 Charles A, Domingo S, Goldfadden A, et al. Small bowel ischemia after Roux-en-Y gastric bypass complicated by pregnancy: a case report. Am Surg. 2005;71(3):231-4. [pmid: 15869139].
72 Kakarla N, Dailey C, Marino T, et al. Pregnancy after gastric bypass surgery and internal hernia formation. Obstet Gynecol. 2005;105(5 Pt 2):1195-8. [pmid: 15863579].
73 Erez O, Maymon E, Mazor M. Acute gastric ulcer perforation in a 35 weeks' nulliparous patient with gastric banding. Am J Obstet Gynecol. 2004;191(5):1721-2. [pmid: 15547550].
74 Moore KA, Ouyang DW, Whang EE. Maternal and fetal deaths after gastric bypass surgery for morbid obesity. N Engl J Med. 2004;351(7):721-2. [pmid: 15306679].
75 Loar PV 3rd, Sanchez-Ramos L, Kaunitz AM, et al. Maternal death caused by midgut volvulus after bariatric surgery. Am J Obstet Gynecol. 2005;193(5):1748-9. [pmid: 16260222].
76 Weissman A, Hagay Z, Schachter M, et al. Severe maternal and fetal electrolyte imbalance in pregnancy after gastric surgery for morbid obesity. A case report. J Reprod Med. 1995;40(11):813-6. [pmid: 8592320].
77 Ramirez MM, Turrentine MA. Gastrointestinal hemorrhage during pregnancy in a patient with a history of vertical-banded gastroplasty. Am J Obstet Gynecol. 1995;173(5):1630-1. [pmid: 7503217].
78 Graubard Z, Graham KM, Schein M. Small-bowel obstruction in pregnancy after Scopinaro weight reduction operation. A case report. S Afr Med J. 1988;73(2):127-8. [pmid: 3340918].
79 Ahmed AR, O'malley W. Internal Hernia with Roux Loop Obstruction during Pregnancy after Gastric Bypass Surgery. Obes Surg. 2006;16(9):1246-8. [pmid: 16989713].
80 Bellanger DE, Ruiz JF, Solar K. Small bowel obstruction complicating pregnancy after laparoscopic gastric bypass. Surg Obes Relat Dis. 2006;2(4):490-2. [pmid: 16925388].
81 Baker MT, Kothari SN. Successful surgical treatment of a pregnancy-induced Petersen's hernia after laparoscopic gastric bypass. Surg Obes Relat Dis. 2005;1(5):506-8. [pmid: 16925279].
82 Gaudry P, Mognol P, Fortin A, et al. [Reflection on one case of acute peritonitis due to adjustable gastric banding during pregnancy]. Gynecol Obstet Fertil. 2006;34(5):407-9. [pmid: 16632401].
83 Fleser PS, Villalba M. Afferent limb volvulus and perforation of the bypassed stomach as a complication of Roux-en-Y gastric bypass. Obes Surg. 2003;13(3):453-6. [pmid: 12841911].
84 Norman RJ, Noakes M, Wu R, et al. Improving reproductive performance in overweight/obese women with effective weight management. Hum Reprod Update. 2004;10(3):267-80. [pmid: 15140873].
85 Crosignani PG, Vegetti W, Colombo M, et al. Resumption of fertility with diet in overweight women. Reprod Biomed Online. 2002;5(1):60-4. [pmid: 12470549].