# Executive Summary

## Introduction

Obesity has reached epidemic proportions in the United States. Along with this increase, weight loss surgeries, known as bariatric procedures, have become increasingly common. This report assesses the incidence of these operations in women of reproductive age and reviews the evidence on the impact of such surgery on fertility, contraception, prepregnancy risk factors, and pregnancy outcomes, including those for neonates.

## Methods

The American College of Obstetricians and Gynecologists (ACOG) nominated the topic of this report and provided the following initial list of questions:

1 What is the incidence of bariatric surgery in women of reproductive age? What are the trends in incidence of bariatric surgery in women of reproductive age?
2 What is the evidence that bariatric surgery affects (directly or indirectly) future fertility?
3 What is the evidence that bariatric surgery affects (directly/indirectly) choice of contraception?
4 In patients who have had bariatric surgery, what is the evidence for prenatal risk factors (e.g., of reduced nutrient absorption, unusual weight gain) that may result in poor pregnancy outcomes?
5 What is the evidence that certain management strategies for addressing nutrient absorption and weight gain reduce the risks of poor pregnancy outcomes?
6 For women who have had bariatric surgery, what is the evidence for morbidity and mortality risks for: a) mother and b) neonate?
7 What is the evidence that cesarean section for women who have had bariatric surgery affects the risks of morbidity and mortality for: a) mother and b) neonate?

To answer key question one, we used the Nationwide Inpatient Sample (NIS), a national sample of over 1,000 hospitals, to measure the trend in the number of women of reproductive age undergoing bariatric procedures from 1998-2005. For key questions two through seven, we searched numerous electronic databases, including Medline and Embase, for potentially relevant studies involving bariatric surgery (gastric bypass, laparoscopic adjustable gastric band, vertical-banded gastroplasty, biliopancreatic diversion), and consequent fertility, contraception, pregnancy, weight management, maternal outcomes, neonatal outcomes, and nutritional deficiencies. We scanned reference lists for additional relevant articles and contacted experts in the fields of bariatric surgery and obstetrics/gynecology (OB/GYN).

We abstracted information about study design, fertility history, fertility outcomes, prepregnancy weight loss, nutritional management, outcomes following pregnancy, and adverse events (during pregnancy) related to surgery. Data are narratively summarized.

## Results

We screened 223 articles. Of those, we accepted 57 studies that reported on the following: fertility following surgery (19 articles), contraception use/recommendations (11), maternal weight or nutrition management (28), maternal outcomes including morbidity and mortality (48), cesarean-section rates (16), and neonatal outcomes (44). (Studies could contribute to more than one analysis.) These reports included gastric bypass, both open and laparoscopic (27 articles), laparoscopic adjustable band (15), biliopancreatic diversion (16), and vertical-banded gastroplasty (six). Only one study was a randomized controlled trial, but it did not have a nonsurgical treatment group, and only one of the three surgical procedures studies is still performed frequently (gastric bypass). Consequently, we treated this study as a case series of gastric bypass. In total, the studies accepted included 12 cohort studies, 21 case series, 23 individual case reports, and one case-control study. Hence, all of the data come from studies with less rigorous designs and therefore the findings are more prone to bias, and, as such, our conclusions are cautious.

### Key Question 1. What is the incidence of bariatric surgery in women of reproductive age? What are the trends in incidence of bariatric surgery in women of reproductive age?

At least 50,000 women between the ages of 18 and 45 undergo bariatric procedures each year in an inpatient setting. The rate of performance of these procedures is increasing rapidly—more than six fold in the past 7 years. Many more women in this age group are also likely undergoing bariatric procedures in the outpatient setting; however these procedures are not reflected in this statistic.

### Key Question 2. What is the evidence that bariatric surgery affects (directly or indirectly) future fertility?

It is likely that fertility improves following bariatric surgery and subsequent weight loss, but this finding is based only on observational data. Fertility did appear to improve for individuals with polycystic ovarian syndrome. These findings are consistent with improvements in fertility seen when obese women lose weight with nonsurgical methods.

### Key Question 3. What is the evidence that bariatric surgery affects (directly/indirectly) choice of contraception?

There is almost no evidence on this topic. We found only a single study that reported data on the effectiveness of contraceptive methods following surgery. A small case series of 40 patients who had undergone biliopancreatic diversion (BPD) and who were advised to avoid pregnancy for at least 2 years reported two failures for oral contraceptives (OCP), one at 9 months postoperatively and the other at 24 months. Based on this, these authors advised the use of something other than OCP, and called for a large RCT to determine the best method of contraception. It is not clear whether the failure rate of OCPs in this case series is significantly worse than expected in average use.

### Key Question 4. In patients who have had bariatric surgery, what is the evidence for prenatal risk factors (e.g., of reduced nutrient absorption, unusual weight gain) that may result in poor pregnancy outcomes?

We did not identify any prospective cohort studies, which would be the strongest study design to assess this question of risk. Consequently, our conclusions are tempered by the limited available evidence. Based on these data, gastric bypass and laparoscopic adjustable band seem to confer minimal if any risk for nutrient problems, as long as maternal nutrition is maintained. However, BPD has an appreciable risk for nutritional problems: In one large case series, 20 percent of pregnant women required parenteral nutrition and case reports of pregnancy following BPD show nutritional adverse events, even with good compliance with supplementation.

### Key Question 5. What is the evidence that certain management strategies for addressing nutrient absorption and weight gain reduce the risks of poor pregnancy outcomes?

It is common practice to recommend nutritional supplementation, such as multi-vitamins and iron, following bariatric surgery for all patients. However, evidence is scarce regarding specific recommendations for pregnant women. We did not identify any randomized studies assessing this question of efficacy of management strategies. Studies evaluating pregnancy following laparoscopic adjustable gastric banding or gastric bypass have shown minimal nutritional adverse events; however, most of these studies monitored and ensured that the women complied with vitamin supplementation. Some case reports/case series stated that the patients who had nutritional deficiencies did not take the recommended supplements. Regarding laparoscopic adjustable gastric band, some reports indicated that the band needed adjustment in order to allow for proper oral nutrition intake.

A number of reports in the literature describe the need for supplementation and parenteral nutrition in pregnancy following BPD. Case series and cohort studies have shown that the rate of parenteral nutrition use in pregnancy after BPD is approximately 20 percent.

### Key Question 6. For women who have had bariatric surgery, what is the evidence for morbidity and mortality risks for: a) mother and b) neonate?

We identified no prospective cohort studies, which would be the strongest study design for this question regarding risk and prognosis, Consequently, our conclusions are tempered by the limited available evidence. Women who have had bariatric surgery may have a lesser risk than obese women for certain pregnancy complications. The one case-control study reported a lower rate of large-for-gestational-age neonates, lower mean birth weights, and less pregnancy-associated hypertension in the postsurgery pregnancies. The observational data, in general, showed lower rates of gestational diabetes, preeclampsia, and pregnancy-induced hypertension in postsurgery pregnancies. In addition, observational studies support that mean birth weight, rates of low birth weight, and rates of premature delivery are similar among babies born to women following bariatric surgery to those in the general population.

There are case reports of surgical complications in women who became pregnant following bariatric surgery, including maternal deaths and fetal death—however there are similar reports in nonpregnant bariatric patients. These complications are uncommon and appeared to be due to internal hernias. Delays in diagnosis were a common factor in many case reports, and use of CT scan, even though the patients were pregnant, was helpful in reaching a diagnosis. Women who elect to have bariatric surgery will have an increased risk of certain complications that would not have occurred had they not had bariatric surgery, but the impact of how pregnancy affects the risk is unknown.

### Key Question 7. What is the evidence that cesarean section for women who have had bariatric surgery affects the risks of morbidity and mortality for: a) mother and b) neonate?

One case control study assessed the effects of cesarean section among women who have had bariatric surgery or their offspring. Comparing 57 women postbariatric surgery and 57 presurgery pregnancies matched for presurgical body mass index, they found no difference in primary or secondary cesarean section rates. In addition, they found no difference in rates of transfusions, peripartum need for antibiotics, or thromboembolic events. The overall rates of cesarean section vary greatly from in the cohort and case series studies. It appears that the obstetric complications are consistent with reports from the nonobese population.

## Discussion

This review has a number of limitations, the most important being the quality of the original studies. The clinical questions of interest are best answered by studies using a prospective cohort design (for studies of risk and prognosis, such as key questions 2 and 4) or randomized clinical trials (for questions of management, such as key questions 3 and 5). We found no such studies, and therefore were compelled to use data from studies with designs of lesser theoretical strength. The inherent limitations in these study designs preclude us from drawing strong conclusions regarding the answers to most questions.

## Future Research

More research is needed to answer almost every key question in this report.

Regarding rates of use, methods are needed to capture the rise in outpatient delivery of bariatric procedures, mainly the laparoscopic adjustable-band. Without this information, estimates of use based on the Nationwide Inpatient Sample will underestimate the total number of cases.

For all issues related to risk and prognosis, such as the effects on fertility, timing of pregnancy, development of complications of pregnancy, outcomes of pregnancy, and cesarean section rates, prospective cohorts are required to provide better estimates.

For the issues related to management, such as choice of contraceptive and nutritional management, randomized controlled trials are needed.

## Conclusions

Weight loss procedures are being performed more frequently to treat morbid obesity, with a six-fold increase over a recent 7-year time span; almost half of patients are women of reproductive age. The level of evidence on fertility, contraception, and pregnancy outcomes is limited primarily to case series and case reports. The evidence suggests that fertility improves after bariatric surgical procedures; however, data are too sparse to reach definite conclusions about the degree of improvement in fertility that is achieved. Evidence also suggests that nutritional deficiencies for mother and child are minimal, and maternal and neonatal outcomes are acceptable with laparoscopic adjustable band and gastric bypass as long as adequate maternal nutrition and vitamin supplementation are maintained.