# Methods

## Original Proposed Key Questions

The American College of Obstetricians and Gynecologists (ACOG) nominated the topic of this report and provided the following initial list of questions:

1 What is the incidence of bariatric surgery in women of reproductive age? What are the trends in incidence of bariatric surgery in women of reproductive age?
2 What is the evidence that bariatric surgery affects (directly or indirectly) future fertility?
3 What is the evidence that bariatric surgery affects (directly/indirectly) choice of contraception?
4 In patients who have had bariatric surgery, what is the evidence for prenatal risk factors (e.g., of reduced nutrient absorption, unusual weight gain) that may result in poor pregnancy outcomes?
5 What is the evidence that certain management strategies for addressing nutrient absorption and weight gain reduce the risks of poor pregnancy outcomes?
6 For women who have had bariatric surgery, what is the evidence for morbidity and mortality risks for: a) mother and b) neonate?
7 What is the evidence that cesarean section for women who have had bariatric surgery affects the risks of morbidity and mortality for: a) mother and b) neonate?

## Technical Expert Panel

Each AHRQ evidence report is guided by a Technical Expert Panel (TEP). We invited a distinguished group of scientists and clinicians, including individuals with expertise in obesity, obstetrics, surgery, pediatrics, and fertility, to participate in the TEP for this report. A list of members is included in Appendix A *. TEP conference calls were held on March 7, 2007, and June 14, 2007. On the first call, staff presented the literature search results and asked experts to suggest additional studies. On the second call, staff presented the study findings and obtained feedback.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/barireptp.htm

## Literature Search

Our search for studies began in November 2006 with an electronic search of PubMed® and Embase for reports on pregnancy after bariatric surgery. We also searched the Cochrane Controlled Clinical Trials Register Database and the Cochrane Database of Reviews of Effectiveness (DARE). (The Cochrane Collaboration is an international organization that helps people make well-informed decisions about health care by preparing, maintaining, and promoting the accessibility of systematic reviews on the effects of heath care interventions.) Search updates were conducted monthly through May 2007.

Appendix B shows our specific search terms. Per our TEP, we included articles on adjustable gastric banding, vertical-banded gastroplasty, Roux-en-Y gastric bypass (RYGB), and biliopancreatic diversion (BPD). Jejunoileal bypass, one of the earliest procedures performed for weight loss, was not included, as this procedure was abandoned about 25 years ago due to a high rate of complications. We used various search terms for each type of procedure. For example, for Roux-en-Y gastric bypass, we also used: gastric bypass, RYGB, laparoscopic gastric bypass, and open gastric bypass. We ordered all articles on pregnancy after bariatric surgery, regardless of study design, language, or publication date.

## Article Review

### Study Inclusion

Our literature search was unrestricted by study design. The studies included in the review are of one of the following types of designs.

- Review articles identified by the search were classified as either systematic (including meta-analyses) or nonsystematic. Systematic reviews were identified by reading the methods section of the article to determine whether an acceptable method was employed to identify evidence (such as a description of the name of the computerized database searched and the full set of search terms used, as well as details about the method for accepting and rejecting identified articles).
- Randomized controlled trials (RCTs) are studies where the participants are definitely assigned prospectively to one of two (or more) alternative forms of intervention, using a process of random allocation (e.g., random number generation, coin flips).
- Controlled clinical trials (CCTs) are studies where participants (or other units) are either
  - definitely assigned prospectively to one of two (or more) alternative forms of health care using a quasi-random allocation method (e.g., alternation, date of birth, patient identifier)
    OR
  - possibly assigned prospectively to one of two (or more) alternative forms of health care using a process of random or quasi-random allocation.
- Observational studies (such as cohort and cases series) are those where the investigators do not control who gets the interventions. Almost all of the data included in this report comes from observational studies.
- Individual case reports are reports of complications / adverse events submitted to medical journals by physicians.

To be included, studies had to report on one of the surgical procedures described in the introduction, and had to report on pregnancy outcomes.

### Screening

Using a single-page “screening form” (included in Appendix C *), we reviewed the studies retrieved from the various sources against our exclusion criteria. Items included specific surgical procedure, study design, sample size, and type of outcome reported (i.e., fertility, morbidity, mortality). Two reviewers, each trained in the critical analysis of scientific literature, independently reviewed each study and resolved disagreements by consensus. The lead investigator resolved any disagreements that remained after discussions between the reviewers.

## Data Abstraction & Synthesis of Results

Results from one case-control study, cohort studies, cases series, and individual case reports were abstracted by physicians into separate data tables. Because of study heterogeneity, pooling was not possible; thus, we summarize the data qualitatively. Data abstracted included surgical adverse events, nutritional deficiencies, and adverse outcomes such as gestational diabetes, hypertension, preeclampsia and macrosomia. Data on miscarriages, premature delivery, and other neonatal outcomes was abstracted where applicable, as was any information on fertility and contraception use/effectiveness.

## Analysis of Trends in Surgery Utilization

We used the Nationwide Inpatient Sample (NIS)^24^ to produce national estimates of trends in bariatric surgical procedures for the years 1998-2005. The NIS is a database of hospital inpatient stays from states participating in the Healthcare Cost and Utilization Project (HCUP). The NIS is the only national hospital inpatient database with charge information on all patients, regardless of payer, including Medicare, Medicaid, private insurance, as well as the uninsured. As the largest such publicly available database it includes data from five to eight million hospital stays from roughly 1,000 hospitals sampled to estimate a 20-percent stratified sample of U.S. community hospitals (all non-Federal, short-term, general, and other specialty hospitals, excluding hospital units of institutions). Because the NIS is available from 1988 to 2005, it allows for a robust analysis of trends over time.

The NIS includes all inpatient discharges within the sampled hospitals. Discharge weights developed by HCUP to account for the sampling scheme were used to produce national estimates. Weights were constructed consistently across the years of data used in our analysis. Hospitals were stratified by region, location/teaching status, bed size category, and ownership. Clustering was accounted for at the hospital level. All analyses were conducted using SAS/STAT® software.^25^

Table 1 displays the International Classification of Diseases 9^th^ Edition (ICD-9) procedure codes for bariatric procedures included in this report. For the seven year time span included in our study, the International Classification of Diseases did not have specific codes for all the bariatric procedures. Previous studies using HCUP data were consulted, they used the Centers for Medicare & Medicaid Services' billing guidelines to compile a comprehensive list of ICD-9 procedure codes that would capture the bariatric operations.^23^ In addition, we accounted for changes in the coding system that occurred. For example, as laparoscopic gastric bypass became more common, a separate code was created for this method. Prior to 2004, gastric bypass, open or laparoscopic, could be coded under a variety of ICD-9 procedure code options, like 44.39 (other gastroenterostomy) or 44.31 (high gastric bypass). In 2004, code 44.38 was created to represent laparoscopic gastric bypass.

Table 1 Bariatric surgical procedures by ICD-9 code

Procedure | | ICD-9 Code
Gastric bypass
| High gastric bypass | 44.31
| Gastroenterostomy other (1998-2005) | 44.39
| Gastroenterostomy - laparoscopic (2004-2005) | 44.38
Gastroplasty
| Gastroplasty - not otherwise specified (1998-2005) | 44.69
| Gastroplasty - laparoscopic (2004-2005) [including vertical banded gastroplasty and those combined with gastroenterostomy] | 44.68
Adjustable Band
| Laparoscopic Adjustable Band (2004-2005) [prior to 2004 coded as 44.69] | 44.95
| Laparoscopic Band revision (2004-2005) [prior to 2004 coded as 44.69] | 44.96
| Laparoscopic band removal (2004-2005) [prior to 2004 coded as 44.99] | 44.97
Malabsorptive
| Sleeve gastrectomy | 43.89
| Partial gastrectomy with jejunal anastomosis | 43.7
| Gastrectomy, distal | 43.6
| Gastrectomy, proximal | 43.5
| Small bowel to small bowel anastomosis | 45.50
| Small bowel segment isolation | 45.51
| Partial resection jejunum | 45.62
| Intestine to intestine anastomosis, not specified | 45.90
| Intestinal isolation, not specified | 45.91
Other | Gastric operation, not specified elsewhere | 44.99

Procedure codes for corresponding gastric procedures were also restricted by ICD-9 codes for obesity (278.0–278.8) or diagnosis-related group code (DRG) for obesity surgery (288). Furthermore, we used several exclusion criteria to decrease the possibility that we were capturing operations not performed for weight loss purposes. Only discharges that had a DRG code for obesity (278 or 288) were included. Emergency admission types were excluded as were cancer (150–159.9) and noninfectious enteritis and colitis (555–558) diagnoses.

Overall estimates of bariatric surgery procedures were calculated for each year of data. Because we were interested in how bariatric surgery affects women of child bearing age, we estimated the number of procedures within the 18–45 age range, overall and by gender. We also performed a subanalysis looking at women between 18–35 and 36–45. The percent change from 1998 was calculated for each of the proceeding years.

## Peer Review

A draft of this report was prepared in July 2007 and sent to the TEP members and national and international experts for review. Peer reviewer comments were considered by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers, and service as a peer reviewer or member of the TEP cannot be construed as endorsement of the report's findings.