# Appendix E. Rejected Titles

## Rejected: At Abstract

1 American College of Obstetricians and Gynecologiests. Guidelines for perinatal care. Washington DC. 2002.
2 Bowne WB, Julliard K, Castro AE, et al. Laparoscopic gastric bypass is superior to adjustable gastric band in super morbidly obese patients: A prospective, comparative analysis. Arch Surg. 2006;141(7):683-9. [pmid: 16847241].
3 Deitel M. Pregnancy after bariatric surgery. Obes Surg. 1998;8:465-6.
4 Deitel M, Ternamian A.M. Gynecologic-obstetric features of morbid obesity and the effect of weight loss. In: Deitel M. (Editor) Update: Surgery for the Morbidly Obese Patient. Toronto: FD-Communications Inc.; 2000. p. 481–5.
5 Higa KD, Tienchin H, Boone KB. Internal hernia after laparoscopic Roux-en-Y gastric bypass: incidence, treatment and prevention. Obes Surg. 2003;13:350-4. [pmid: 12841892].
6 Houston BD, Turner T. Severe electrolyte abnormalities in a pregnant patient with a jejunoileal bypass. Arch Intern Med. 1978;138(11):1712-3. [pmid: 718324].
7 Hrgovic Z, Alnor PC. [Pregnancy after treatment of obesity using jejuno-ileal anastomosis]. Jugosl Ginekol Perinatol. 1985;25(12):39-41. [pmid: 4087931].
8 Pugnale N, Giusti V, Suter M, et al. Bone metabolism and risk of secondary hyperparathyroidism 12 months after gastric banding in obese pre-menopausal women. Int J Obes Relat Metab Disord. 2003;27(1):110-6. [pmid: 12532162].
9 Schein M. Collar material erosion after vertical-banded gastroplasty—an underestimated problem? A case report. S Afr J Surg. 1990;28(2):73-4. [pmid: 2382169].
10 Smets RM, Waeben M. Unusual combination of night blindness and optic neuropathy after biliopancreatic bypass. Bull Soc Belge Ophtalmol. 1999;271:93-6. [pmid: 10355165].

## Rejected: Not Bariatric Surgery

1 ACOG Committee Opinion. Number 299, September 2004 (replaces No. 158, September 1995). Guidelines for diagnostic imaging during pregnancy. Obstet Gynecol 2004;104(3):647–51.
2 Safety considerations and avoiding complications in the massive weight loss patient. Plast Reconstr Surg 2006;117(1 Suppl):74S–81S; discussion 82S–83S.
3 Abrams B, Parker JD. Maternal weight gain in women with good pregnancy outcome. Obstet Gynecol. 1990;76(1):1-7. [pmid: 2359553].
4 Akira S, Abe T, Igarashi K, et al. Gasless laparoscopic surgery using a new intra-abdominal fan retractor system: an experience of 500 cases. J Nippon Med Sch. 2005;72(4):213-6. [pmid: 16113491].
5 Andreasen KR, Andersen ML, Schantz AL. Obesity and pregnancy. Acta Obstet Gynecol Scand. 2004;83(11):1022-9. [pmid: 15488115].
6 Baeten JM, Bukusi EA, Lambe M. Pregnancy complications and outcomes among overweight and obese nulliparous women. Am J Public Health. 2001;91(3):436-40. [pmid: 11236410]. [pmcid: 1446581].
7 Beck WW Jr. Intestinal obstruction in pregnancy. Obstet Gynecol. 1974;43(3):374-8. [pmid: 4814455].
8 Belsey EM, d'Arcangues C, Carlson N. Determinants of menstrual bleeding patterns among women using natural and hormonal methods of contraception. II. The influence of individual characteristics. Contraception. 1988;38(2):243-57. [pmid: 2971508].
9 Bowers D, Cohen WR. Obesity and related pregnancy complications in an inner-city clinic. J Perinatol. 1999;19(3):216-9. [pmid: 10685225].
10 Calandra C, Abell DA, Beischer NA. Maternal obesity in pregnancy. Obstet Gynecol. 1981;57(1):8-12. [pmid: 6969873].
11 Cedergren MI. Maternal morbid obesity and the risk of adverse pregnancy outcome. Obstet Gynecol. 2004;103(2):219-24. [pmid: 14754687].
12 Cnattingius R, Cnattingius S, Notzon FC. Obstacles to reducing cesarean rates in a low-cesarean setting: the effect of maternal age, height, and weight. Obstet Gynecol. 1998;92(4 Pt 1):501-6. [pmid: 9764619].
13 Cnattingius R, Hoglund B, Kieler H. Emergency cesarean delivery in induction of labor: an evaluation of risk factors. Acta Obstet Gynecol Scand. 2005;84(5):456-62. [pmid: 15842210].
14 Cnattingius S, Bergstrom R, Lipworth L, et al. Prepregnancy weight and the risk of adverse pregnancy outcomes. N Engl J Med. 1998;338(3):147-52. [pmid: 9428815].
15 Crane SS, Wojtowycz MA, Dye TD, et al. Association between pre-pregnancy obesity and the risk of cesarean delivery. Obstet Gynecol. 1997;89(2):213-6. [pmid: 9015022].
16 Crerand CE, Wadden TA, Sarwer DB, et al. A comparison of weight histories in women with class III vs. class I–II obesity. Surg Obes Relat Dis. 2006;2(2):165-70. [pmid: 16925343].
17 Crerand CE, Wadden TA, Sarwer DB, et al. A comparison of weight histories in women with class III vs. class I–II obesity. Obesity (Silver Spring). 2006;14(Suppl 2):63S-69S. [pmid: 16648596].
18 Crosignani PG, Vegetti W, Colombo M, et al. Resumption of fertility with diet in overweight women. Reprod Biomed Online. 2002;5(1):60-4. [pmid: 12470549].
19 Curet MJ. Special problems in laparoscopic surgery. Previous abdominal surgery, obesity, and pregnancy. Surg Clin North Am. 2000;80(4):1093-110. [pmid: 10987026].
20 Davis MR, Bohon CJ. Intestinal obstruction in pregnancy. Clin Obstet Gynecol. 1983;26(4):832-42. [pmid: 6661838].
21 De Sutter P. Rational diagnosis and treatment in infertility. Best Pract Res Clin Obstet Gynaecol. 2006;20(5):647-64. [pmid: 16769249].
22 Dempsey JC, Ashiny Z, Qiu CF, et al. Maternal pre-pregnancy overweight status and obesity as risk factors for cesarean delivery. J Matern Fetal Neonatal Med. 2005;17(3):179-85. [pmid: 16147820].
23 Durnwald CP, Ehrenberg HM, Mercer BM. The impact of maternal obesity and weight gain on vaginal birth after cesarean section success. Am J Obstet Gynecol. 2004;191(3):954-7. [pmid: 15467571].
24 Ehrenberg HM, Durnwald CP, Catalano P, et al. The influence of obesity and diabetes on the risk of cesarean delivery. Am J Obstet Gynecol. 2004;191(3):969-74. [pmid: 15467574].
25 Ekblad U, Grenman S. Maternal weight, weight gain during pregnancy and pregnancy outcome. Int J Gynaecol Obstet. 1992;39(4):277-83. [pmid: 1361460].
26 Ferreira MF, Sobrinho LG, Pires JS, et al. Endocrine and psychological evaluation of women with recent weight gain. Psychoneuroendocrinology. 1995;20(1):53-63. [pmid: 7838902].
27 Finlay M, Huang LL. A new variant of serum leucine aminopeptidase in the mouse: its development and possible regulation. Biochem Genet. 1985;23(12):169-80. [pmid: 3857912].
28 Galtier-Dereure F, Boulot P. [Obstetrical complications of maternal overweight]. Contracept Fertil Sex. 1994;22(2):113-6. [pmid: 8199642].
29 Galtier-Dereure F, Montpeyroux F, Boulot P, et al. Weight excess before pregnancy: complications and cost. Int J Obes Relat Metab Disord. 1995;19(7):443-8. [pmid: 8520632].
30 Goldman M, Kitzmiller JL, Abrams B, et al. Obstetric complications with GDM. Effects of maternal weight. Diabetes. 1991;40(Suppl 2):79-82. [pmid: 1748271].
31 Goodall PT, Ahn JT, Chapa JB, et al. Obesity as a risk factor for failed trial of labor in patients with previous cesarean delivery. Am J Obstet Gynecol. 2005;192(5):1423-6. [pmid: 15902126].
32 Gray DS, Cabaniss ML. Home total parenteral nutrition in a pregnant diabetic after jejunoileal bypass for obesity. JPEN J Parenter Enteral Nutr. 1989;13(2):214-7. [pmid: 2496253].
33 Grimes DA, Shields WC. Family planning for obese women: challenges and opportunities. Contraception. 2005;72(1):1-4. [pmid: 15964284].
34 Grossetti E, Beucher G, Regeasse A, et al. [Obstetrical complications of morbid obesity]. J Gynecol Obstet Biol Reprod (Paris). 2004;33(8):739-44. [pmid: 15687946].
35 Hanker JP. Gastrointestinal disease and oral contraception. Am J Obstet Gynecol. 1990;163(6 Pt 2):2204-7. [pmid: 2256527].
36 Hendler I, Schatz M, Momirova V, et al. Association of obesity with pulmonary and nonpulmonary complications of pregnancy in asthmatic women. Obstet Gynecol. 2006;108(1):77-82. [pmid: 16816059].
37 Hood DD, Dewan DM. Anesthetic and obstetric outcome in morbidly obese parturients. Anesthesiology. 1993;79(6):1210-8. [pmid: 8267196].
38 Hung MJ, Liu FS, Shen PS, et al. Analysis of two sling procedures using polypropylene mesh for treatment of stress urinary incontinence. Int J Gynaecol Obstet. 2004;84(2):133-41. [pmid: 14871515].
39 Isaacs JD, Magann EF, Martin RW, et al. Obstetric challenges of massive obesity complicating pregnancy. J Perinatol. 1994;14(1):10-4. [pmid: 8169671].
40 Jensen DM, Damm P, Sorensen B, et al. Pregnancy outcome and prepregnancy body mass index in 2459 glucose-tolerant Danish women. Am J Obstet Gynecol. 2003;189(1):239-44. [pmid: 12861169].
41 Jensen H, Agger AO, Rasmussen KL. The influence of prepregnancy body mass index on labor complications. Acta Obstet Gynecol Scand. 1999;78(9):799-802. [pmid: 10535344].
42 Johnson SR, Kolberg BH, Varner MW, et al. Maternal obesity and pregnancy. Surg Gynecol Obstet. 1987;164(5):431-7. [pmid: 3576419].
43 Juhasz G, Gyamfi C, Gyamfi P, et al. Effect of body mass index and excessive weight gain on success of vaginal birth after cesarean delivery. Obstet Gynecol. 2005;106(4):741-6. [pmid: 16199630].
44 Kabiru W, Raynor BD. Obstetric outcomes associated with increase in BMI category during pregnancy. Am J Obstet Gynecol. 2004;191(3):928-32. [pmid: 15467566].
45 Kaiser PS, Kirby RS. Obesity as a risk factor for cesarean in a low-risk population. Obstet Gynecol. 2001;97(1):39-43. [pmid: 11152904].
46 Khorshid EA, Elbeheidy TA, Quinaibi AM. Risk of morbid obesity with pregnancy. Saudi Med J. 2004;25(1):121-2. [pmid: 14758400].
47 Knudsen LB, Kallen B. Intestinal bypass operation and pregnancy outcome. Acta Obstet Gynecol Scand. 1986;65(8):831-4. [pmid: 3825522].
48 Kral JG. Patient selection for treatment of obesity. Surg Obes Relat Dis. 2005;1(2):126-32. [pmid: 16925228].
49 Krishnamoorthy U, Schram CM, Hill SR. Maternal obesity in pregnancy: Is it time for meaningful research to inform preventive and management strategies?. BJOG. 2006;113(10):1134-40. [pmid: 16972858].
50 Kumari AS. Pregnancy outcome in women with morbid obesity. Int J Gynaecol Obstet. 2001;73(2):101-7. [pmid: 11336728].
51 Legato MJ. Gender-specific aspects of obesity. Int J Fertil Womens Med. 1997;42(3):184-97. [pmid: 9222803].
52 Lu GC, Rouse DJ, DuBard M, et al. The effect of the increasing prevalence of maternal obesity on perinatal morbidity. Am J Obstet Gynecol. 2001;185(4):845-9. [pmid: 11641663].
53 Maden M. Vitamin A and the developing embryo. Postgrad Med J. 2001;77(910):489-91. [pmid: 11470926]. [pmcid: 1742091].
54 Mancuso A, D'Anna R, Leonardi R. Pregnancy in the obese patient. Eur J Obstet Gynecol Reprod Biol. 1991;39(2):83-6. [pmid: 2050258].
55 McClain CJ, Kasarskis EJ Jr, Allen JJ. Functional consequences of zinc deficiency. Prog Food Nutr Sci. 1985;9(12):185-226. [pmid: 3911268].
56 Morton A. Obesity and pregnancy. Acta Obstet Gynecol Scand. 2005;84(7):709-10. [pmid: 15954888].
57 Murakami M, Ohmichi M, Takahashi T, et al. Prepregnancy body mass index as an important predictor of perinatal outcomes in Japanese. Arch Gynecol Obstet. 2005;271(4):311-5. [pmid: 15185098].
58 O'Brien PE, Dixon JB. A rational approach to cholelithiasis in bariatric surgery: its application to the laparoscopically placed adjustable gastric band. Arch Surg. 2003;138(8):908-12. [pmid: 12912752].
59 O'Brien WF. Weight control in women: a challenge to the obstetrician-gynecologist. Obstet Gynecol. 1996;88(5):888-90. [pmid: 8885934].
60 Oddens BJ, Visser AP, Vemer HM, et al. Contraceptive use and attitudes in Great Britain. Contraception. 1994;49(1):73-86. [pmid: 8137627].
61 Perlow JH, Morgan MA. Massive maternal obesity and perioperative cesarean morbidity. Am J Obstet Gynecol. 1994;170(2):560-5. [pmid: 8116713].
62 Perlow JH, Morgan MA, Montgomery D, et al. Perinatal outcome in pregnancy complicated by massive obesity. Am J Obstet Gynecol. 1992;167(4 Pt 1):958-62. [pmid: 1415432].
63 Pole JD, Dodds LA. Maternal outcomes associated with weight change between pregnancies. Can J Public Health. 1999;90(4):233-6. [pmid: 10489718].
64 Poots S, Logmans A, Duvekot JJ, et al. [Morbid obesity: a risk factor for obstetric complications]. Ned Tijdschr Geneeskd. 2004;148(46):2253-6. [pmid: 15584537].
65 Ramos GA, Caughey AB. The interrelationship between ethnicity and obesity on obstetric outcomes. Am J Obstet Gynecol. 2005;193(3 Pt 2):1089-93. [pmid: 16157117].
66 Ranta P, Jouppila P, Spalding M, et al. The effect of maternal obesity on labour and labour pain. Anaesthesia. 1995;50(4):322-6. [pmid: 7747849].
67 Rasmussen KL, Linnet KM, Jensen H, et al. Morbidity after cesarean section in obese women. Acta Obstet Gynecol Scand. 1998;77(7):782-3. [pmid: 9740529].
68 Ratner RE, Hamner LH 3rd, Isada NB. Effects of gestational weight gain in morbidly obese women: I. Maternal morbidity. Am J Perinatol. 1991;8(1):21-4. [pmid: 1987961].
69 Ratner RE, Hamner LH 3rd, Isada NB. Effects of gestational weight gain in morbidly obese women: II: Fetal morbidity. Am J Perinatol. 1990;7(4):295-9. [pmid: 2222615].
70 Ray JG, Vermeulen MJ, Shapiro JL, et al. Maternal and neonatal outcomes in pregestational and gestational diabetes mellitus, and the influence of maternal obesity and weight gain: the DEPOSIT study. Diabetes Endocrine Pregnancy Outcome Study in Toronto. QJM. 2001;94(7):347-56. [pmid: 11435630].
71 Rode L, Nilas L, Wojdemann K, et al. Obesity-related complications in Danish single cephalic term pregnancies. Obstet Gynecol. 2005;105(3):537-42. [pmid: 15738021].
72 Rosenberg TJ, Garbers S, Lipkind H, et al. Maternal obesity and diabetes as risk factors for adverse pregnancy outcomes: differences among 4 racial/ethnic groups. Am J Public Health. 2005;95(9):1545-51. [pmid: 16118366]. [pmcid: 1449396].
73 Rothman KJ, Moore LL, Singer MR, et al. Teratogenicity of high vitamin A intake. N Engl J Med. 1995;333(21):1369-73. [pmid: 7477116].
74 Ruge S, Andersen T. Obstetric risks in obesity. An analysis of the literature. Obstet Gynecol Surv. 1985;40(2):57-60. [pmid: 3883256].
75 Saravanakumar K, Rao SG, Cooper GM. Obesity and obstetric anaesthesia. Anaesthesia. 2006;61(1):36-48. [pmid: 16409341].
76 Sobande AA, Al-Bar H, Archibong EI. Diabetes and perinatal loss. A continuing problem. Saudi Med J. 2000;21(2):161-3. [pmid: 11533773].
77 Stany MP, Winter WE 3rd, Dainty L, et al. Laparoscopic exposure in obese high-risk patients with mechanical displacement of the abdominal wall. Obstet Gynecol. 2004;103(2):383-6. [pmid: 14754711].
78 Sukalich S, Mingione MJ, Glantz JC. Obstetric outcomes in overweight and obese adolescents. Am J Obstet Gynecol. 2006;195(3):851-5. [pmid: 16949425].
79 Tilton Z, Hodgson MI, Donoso E, et al. Complications and outcome of pregnancy in obese women. Nutrition. 1989;5(2):95-9. [pmid: 2520281].
80 Tingthanatikul Y, Choktanasiri W, Rochanawutanon M, et al. Prevalence and clinical predictors of endometrial hyperplasiain anovulatory women presenting with amenorrhea. Gynecol Endocrinol. 2006;22(2):101-5. [pmid: 16603436].
81 Tsen LC. What's new and novel in obstetric anesthesia? Contributions from the 2003 scientific literature. Int J Obstet Anesth. 2005;14(2):126-46. [pmid: 15795148].
82 Usha Kiran TS, Hemmadi S, Bethel J, et al. Outcome of pregnancy in a woman with an increased body mass index. BJOG. 2005;112(6):768-72. [pmid: 15924535].
83 Vahratian A, Siega-Riz AM, Savitz DA, et al. Maternal pre-pregnancy overweight and obesity and the risk of cesarean delivery in nulliparous women. Ann Epidemiol. 2005;15(7):467-74. [pmid: 15921926].
84 Vahratian A, Zhang J, Troendle JF, et al. Maternal prepregnancy overweight and obesity and the pattern of labor progression in term nulliparous women. Obstet Gynecol. 2004;104(5 Pt 1):943-51. [pmid: 15516383].
85 von Ungern-Sternberg BS, Regli A, Bucher E, et al. Impact of spinal anaesthesia and obesity on maternal respiratory function during elective Caesarean section. Anaesthesia. 2004;59(8):743-9. [pmid: 15270963].
86 Weiss JL, Malone FD, Emig D, et al. Obesity, obstetric complications and cesarean delivery rate—a population-based screening study. Am J Obstet Gynecol. 2004;190(4):1091-7. [pmid: 15118648].
87 Wills CE Jr. Gastric bypass for morbid obesity. J Med Assoc Ga. 1981;70(10):725-7. [pmid: 7338675].
88 Young TK, Woodmansee B. Factors that are associated with cesarean delivery in a large private practice: the importance of prepregnancy body mass index and weight gain. Am J Obstet Gynecol. 2002;187(2):312-8. discussion 318–20. [pmid: 12193918].

## Rejected: Not Focus or Topic of Interest

1 Abramovici H, Brandes JM, Schramek A. Small for gestational age infants in pregnancies following jejunoileal bypass. Int Surg. 1980;65(2):135-7. [pmid: 7194325].
2 Abu-Abeid S, Gavert N, Klausner JM, et al. Bariatric surgery in adolescence. J Pediatr Surg. 2003;38(9):1379-82. [pmid: 14523824].
3 Apovian CM, Baker C, Ludwig DS, et al. Best practice guidelines in pediatric/adolescent weight loss surgery. Obes Res. 2005;13(2):274-82. [pmid: 15800284].
4 Barreto Villela N, Braghrolli Neto O, Lima Curvello K, et al. Quality of life of obese patients submitted to bariatric surgery. Nutr Hosp. 2004;19(6):367-71. [pmid: 15672653].
5 Bastounis EA, Karayiannakis AJ, Syrigos K, et al. Sex hormone changes in morbidly obese patients after vertical banded gastroplasty. Eur Surg Res. 1998;30(1):43-7. [pmid: 9493693].
6 Bertolotto M, Gianetta E, Rollandi GA, et al. Imaging of patients with pancreaticobiliary diversion for obesity: post-operative anatomy and findings in small bowel obstruction. Br J Radiol. 1996;69(824):708-6. [pmid: 8949672].
7 Bouldin MJ, Ross LA, Sumrall CD, et al. The effect of obesity surgery on obesity comorbidity. Am J Med Sci. 2006;331(4):183-93. [pmid: 16617233].
8 Brolin RE. Update: NIH consensus conference. Gastrointestinal surgery for severe obesity. Nutrition. 1996;12(6):403-4. [pmid: 8875533].
9 Brooke OG, Abernethy E. Growth of the foetus and infant following maternal jejuno-ileal bypass for obesity: a case report. Hum Nutr Appl Nutr. 1984;38(4):308-10. [pmid: 6490400].
10 Brown W, Dixon JB, Brien PO. Management of obesity—the role of surgery. Aust Fam Physician. 2006;35(8):584-6. [pmid: 16894430].
11 Bump RC, Sugerman HJ, Fantl JA, et al. Obesity and lower urinary tract function in women: effect of surgically induced weight loss. Am J Obstet Gynecol. 1992;167(2):392-7. discussion 397–9. [pmid: 1497041].
12 Capizzi FD, Boschi S, Brulatti M, et al. Laparoscopic adjustable esophagogastric banding: preliminary results. Obes Surg. 2002;12(3):391-4. [pmid: 12082894].
13 Champion JK, Williams M, Champion S, et al. Implantable gastric stimulation to achieve weight loss in patients with a low body mass index: early clinical trial results. Surg Endosc. 2006;20(3):444-7. [pmid: 16437276].
14 Colquitt J, Clegg A, Sidhu M, et al. Surgery for morbid obesity. Cochrane Database Syst Rev 2005;(4):CD003641.
15 De Waele B, Lauwers M, Van Nieuwenhove Y, et al. Outpatient laparoscopic gastric banding: initial experience. Obes Surg. 2004;14(8):1108-10. [pmid: 15479601].
16 Dixon JB, Dixon ME, O'Brien PE. Elevated homocysteine levels with weight loss after Lap Band Surgery: higher folate and vitamin B-12 levels required to maintain homocysteine level. Int J Obes. 2001;25(2):219-27.
17 Dixon JB, O'Brien PE. Selecting the optimal patient for LAP-BAND placement. Am J Surg. 2002;184(6B):17S-20S. [pmid: 12527345].
18 Dolan K, Creighton L, Hopkins G, et al. Laparoscopic gastric banding in morbidly obese adolescents. Obes Surg. 2003;13(1):101-4. [pmid: 12630622].
19 Dolan K, Fielding G. A comparison of laparoscopic adjustable gastric banding in adolescents and adults. Surg Endosc. 2004;18(1):45-7. [pmid: 14625730].
20 Doldi SB, Micheletto G, Lattuada E, et al. Adjustable gastric banding: 5-year experience. Obes Surg. 2000;10(2):171-3. [pmid: 10782180].
21 Edwards JE. Pregnancy after bariatric surgery. AWHONN Lifelines. 2005;9(5):388-93. [pmid: 16359078].
22 Favretti F, O'Brien PE, Dixon JB. Patient management after LAP-BAND placement. Am J Surg. 2002;184(6B):38S-41S. [pmid: 12527349].
23 Fernandes M, Atallah A, Soares B, et al. Intragastric balloon for obesity. Cochrane Database Syst Rev 2007;(1):CD004931.
24 Forsell P, Hellers G. The Swedish Adjustable Gastric Banding (SAGB) for morbid obesity: 9 year experience and a 4-year follow-up of patients operated with a new adjustable band. Obes Surg. 1997;7(4):345-51. [pmid: 9730522].
25 Gosman GG, Katcher HI, Legro RS. Obesity and the role of gut and adipose hormones in female reproduction. Hum Reprod Update. 2006;12(5):585-601. [pmid: 16775192].
26 Grimm IS, Schindler W, Haluszka O. Steatohepatitis and fatal hepatic failure after biliopancreatic diversion. Am J Gastroenterol. 1992;87(6):775-9. [pmid: 1590319].
27 Hey H, Niebuhr-Jorgensen U. Jejuno-ileal bypass surgery in obesity. Gynecological and obstetrical aspects. Acta Obstet Gynecol Scand. 1981;60(2):135-40. [pmid: 7246078].
28 Horgan S, Holterman MJ, Jacobsen GR, et al. Laparoscopic adjustable gastric banding for the treatment of adolescent morbid obesity in the United States: a safe alternative to gastric bypass. J Pediatr Surg. 2005;40(1):86-90. discussion 90–1. [pmid: 15868564].
29 Ingardia CJ, Fischer JR. Pregnancy after jejunoileal bypass and the SGA infant. Obstet Gynecol. 1978;52(2):215-8. [pmid: 683662].
30 Inge TH, Garcia V, Daniels S, et al. A multidisciplinary approach to the adolescent bariatric surgical patient. J Pediatr Surg. 2004;39(3):442-7. discussion 446–7. [pmid: 15017567].
31 Johns A, Staples PP. Coagulation defects associated with jejunoileal bypass and term pregnancy. South Med J. 1979;72(1):79-81. [pmid: 760229].
32 Kalfarentzos F, Skroubis G, Kehagias I, et al. A prospective comparison of vertical banded gastroplasty and Roux-en-Y gastric bypass in a non-superobese population. Obes Surg. 2006;16(2):151-8. [pmid: 16469216].
33 Karlsson J, Sjostrom L, Sullivan M. Swedish obese subjects (SOS)—an intervention study of obesity. Two-year follow-up of health-related quality of life (HRQL) and eating behavior after gastric surgery for severe obesity. Int J Obes Relat Metab Disord. 1998;22(2):113-26. [pmid: 9504319].
34 Kelly J, Tarnoff M, Shikora S, et al. Best practice recommendations for surgical care in weight loss surgery. Obes Res. 2005;13(2):227-33. [pmid: 15800278].
35 Knudsen LB, Kallen B. Gastric bypass, pregnancy, and neural tube defects. Lancet. 1986;2(8500):227. [pmid: 2873476].
36 Kral JG, Brolin RE, Buchwald H, et al. Research considerations in obesity surgery. Obes Res. 2002;10(1):63-4. [pmid: 11786604].
37 Kushner R. Managing the obese patient after bariatric surgery: a case report of severe malnutrition and review of the literature. JPEN J Parenter Enteral Nutr. 2000;24(2):126-32. [pmid: 10772194].
38 Kushner RF, Gleason B, Shanta-Retelny V. Reemergence of pica following gastric bypass surgery for obesity: a new presentation of an old problem. J Am Diet Assoc. 2004;104(9):1393-7. [pmid: 15354156].
39 Kushner RF, Noble CA. Long-Term Outcome of Bariatric Surgery: an Interim Analysis. Mayo Clinic Proceedings. 2006;81(10):S46-S51. [pmid: 17036578].
40 Lee WJ, Yu PJ, Wang W, et al. Laparoscopic Roux-en-Y versus mini-gastric bypass for the treatment of morbid obesity: a prospective randomized controlled clinical trial. Ann Surg. 2005;242(1):20-8. [pmid: 15973097]. [pmcid: 1357700].
41 LoIudice TA, Chandrakaar C. Pregnancy and jejunoileal bypass: treatment of complications with total parenteral nutrition. South Med J. 1980;73(2):256-8. [pmid: 6766572].
42 Macgregor AM. Small Bowel Obstruction Following Gastric Bypass. Obes Surg. 1992;2(4):333-339. [pmid: 10765193].
43 Msika S. [Surgery for morbid obesity: 2. Complications. Results of a Technologic Evaluation by the ANAES]. J Chir (Paris). 2003;140(1):4-21. [pmid: 12709648].
44 Naslund I. Gastric bypass versus gastroplasty. A prospective study of differences in two surgical procedures for morbid obesity. Acta Chir Scand Suppl. 1987;536:1-60. [pmid: 3475886].
45 Naslund I, Hallgren P, Sjostrom L. Fat cell weight and number before and after gastric surgery for morbid obesity in women. Int J Obes. 1988;12(3):191-7. [pmid: 3391735].
46 Naslund I, Wickbom G, Christoffersson E, et al. A prospective randomized comparison of gastric bypass and gastroplasty. Complications and early results. Acta Chir Scand. 1986;152:681-9. [pmid: 3551425].
47 O'Brien PE, Dixon JB, Brown W, et al. The laparoscopic adjustable gastric band (Lap-Band): a prospective study of medium-term effects on weight, health and quality of life. Obes Surg. 2002;12(5):652-60. [pmid: 12448387].
48 O'Brien PE, Dixon JB, Laurie C, et al. Treatment of mild to moderate obesity with laparoscopic adjustable gastric banding or an intensive medical program: a randomized trial. Ann Intern Med. 2006;144(9):625-33. [pmid: 16670131].
49 Parikh M, Duncombe J, Fielding GA. Laparoscopic adjustable gastric banding for patients with body mass index of <or=35 kg/m2. Surg Obes Relat Dis. 2006;2(5):518-22. [pmid: 17015204].
50 Rubenstein RB. Laparoscopic adjustable gastric banding at a U.S. center with up to 3-year follow-up. Obes Surg. 2002;12(3):380-4. [pmid: 12082892].
51 Schilling RF, Gohdes PN, Hardie GH. Vitamin B12 deficiency after gastric bypass surgery for obesity. Ann Intern Med. 1984;101(4):501-2. [pmid: 6476636].
52 Silber T, Randolph J, Robbins S. Long-term morbidity and mortality in morbidly obese adolescents after jejunoileal bypass. J Pediatr. 1986;108(2):318-22. [pmid: 3944722].
53 Song AY, Rubin JP, Thomas V, et al. Body image and quality of life in post massive weight loss body contouring patients. Obesity (Silver Spring). 2006;14(9):1626-36. [pmid: 17030974].
54 Stanford A, Glascock JM, Eid GM, et al. Laparoscopic Roux-en-Y gastric bypass in morbidly obese adolescents. J Pediatr Surg. 2003;38(3):430-3. [pmid: 12632362].
55 Sugerman HJ, Sugerman EL, DeMaria EJ, et al. Bariatric surgery for severely obese adolescents. J Gastrointest Surg. 2003;7(1):102-7. discussion 107–8. [pmid: 12559191].
56 Sumner AE, Chin MM, Abrahm JL, et al. Elevated methylmalonic acid and total homocysteine levels show high prevalence of vitamin B12 deficiency after gastric surgery. Ann Intern Med. 1996;124(5):469-76. [pmid: 8602704].
57 Tonstad S, Sundfor T, Myrvoll EA. [Nutritional status after surgical treatment of obesity]. Tidsskr Nor Laegeforen. 2007;127(1):50-3. [pmid: 17205091].
58 Victor A, Odlind V, Kral JG. Oral contraceptive absorption and sex hormone binding globulins in obese women: effects of jejunoileal bypass. Gastroenterol Clin North Am. 1987;16(3):483-91. [pmid: 2449395].
59 Westgate FG, Birmingham CL. Gastric Banding for Morbid Obesity: the St Paul's experience. Obes Surg. 1991;1(3):287-291. [pmid: 10775926].
60 Yashkov YI, Vinnitsky LI, Poroykova MV, et al. Some hormonal changes before and after vertical banded gastroplasty for severe obesity. Obes Surg. 2000;10(1):48-53. [pmid: 10715645].

## Rejected: Study Design - Non-systematic Review

1 ACOG Committee Opinion number 315, September 2005. Obesity in pregnancy. Obstet Gynecol 2005;106(3):671–5.
2 Burt J. Worth the weight: pregnancy after gastric bypass surgery. Adv Nurse Pract. 2005;13(11):45-7. [pmid: 16295002].
3 Dixon JB, O'Brien PE. Changes in comorbidities and improvements in quality of life after LAP-BAND placement. Am J Surg. 2002;184(6B):51S-54S. [pmid: 12527352].
4 Hall LF, Neubert AG. Obesity and pregnancy. Obstet Gynecol Surv. 2005;60(4):253-60. [pmid: 15795633].
5 Herrera B. Pregnancy after weight loss surgery: can it be healthy? Midwifery Today Int Midwife 2005;(74):33.
6 Inge TH, Krebs NF, Garcia VF, et al. Bariatric surgery for severely overweight adolescents: concerns and recommendations. Pediatrics. 2004;114(1):217-23. [pmid: 15231931].
7 Lara MD, Kothari SN, Sugerman HJ. Surgical management of obesity: a review of the evidence relating to the health benefits and risks. Treat Endocrinol. 2005;4(1):55-64. [pmid: 15649101].
8 Lynch RJ, Eisenberg D, Bell RL. Metabolic consequences of bariatric surgery. J Clin Gastroenterol. 2006;40(8):659-68. [pmid: 16940875].
9 Merhi ZO. Weight loss by bariatric surgery and subsequent fertility. Fertil Steril. 2007;87(2):430-2. [pmid: 17113090].
10 O'Brien PE, Dixon JB. Laparoscopic adjustable gastric banding in the treatment of morbid obesity. Arch Surg. 2003;138(4):376-82. [pmid: 12686523].
11 Raymond RH. Hormonal status, fertility, and pregnancy before and after bariatric surgery. Crit Care Nurs Q. 2005;28(3):263-8. [pmid: 16041226].
12 Wong KH, Leader A, Deitel M. Maternal nutrition in pregnancy. Part II: the implications of previous gastrointestinal operations and bowel disorders. Can Med Assoc J. 1981;125(6):550-2. [pmid: 7026014]. [pmcid: 1862625].
13 Woodard CB. Pregnancy following bariatric surgery. J Perinat Neonatal Nurs. 2004;18(4):329-40. [pmid: 15646304].
14 Xanthakos SA, Inge TH. Nutritional consequences of bariatric surgery. Curr Opin Clin Nutr Metab Care. 2006;9(4):489-96. [pmid: 16778582].

## Rejected: Study Design - Review / Meta-analysis

1 Van Hee RH. Biliopancreatic diversion in the surgical treatment of morbid obesity. World J Surg. 2004;28(5):435-44. [pmid: 15085390].

## Rejected: Study Design - Background Article

1 Casco Bay Surgery. Bariatric surgery program: Guidelines for preconception and prenatal care following bariatric surgery. available at URL: http://www.cascobaysurgery.com/Bariatric%20Surgery%20Program/prenatal%20care.htm. Accessed 2/14/2007.