# Appendix D. Evidence Table

Bariatric Surgery for Women of Reproductive Age Overall Evidence Table

First Author Year | Type of Surgery | Study Design | Sample Size | Years Surgery Performed | Selection Criteria
AHMED 2006^70^ | Gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
BAKER 2005^72^ | Gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
BAR-ZOHAR 2006^58^ | Adjustable gastric banding | Case series | 74 | 1996-2003 | Selected sample
BELLANGER 2006^71^ | Gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
BILENKA 1995^26^ | Vertical banded gastroplasty | Cohort | 9 | 1985-1990 | Assembly method not reported
BIRON 1999^60^ | Biliopancreatic diversion | Case series | 544 | Pre 1995 | Consecutive patients
CAMPBELL 2005^50^ | Gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
CHAPMAN 1991^61^ | Vertical banded gastroplasty | Case report | 1 | NR | Not applicable (not cohort study)
COOLS 2006^44^ | Biliopancreatic diversion | Case series | 9 | NR | Assembly method not reported
DAO 2006^41^ | Gastric bypass | Cohort | 2423 | 2001-2004 | Selected sample
DEITEL 1988^25^ | Biliopancreatic diversion, Vertical banded gastroplasty | Cohort | 138 | 1977-1984 | Selected sample
DIXON 2001^30^ | Adjustable gastric banding | Cohort | 650 | NR | Assembly method not reported
DIXON 2005^39^ | Adjustable gastric banding | Cohort | 79 | 1995-2003 | Selected sample
DOMINGO 2005^65^ | Gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
EID 2005^36^ | Gastric bypass | Cohort | 24 | 1997-2001 | Selected sample
EREZ 2004^77^ | Adjustable gastric banding | Case report | 1 | NR | Not applicable (not cohort study)
FLESER 2003^73^ | Gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
FRIEDMAN 1989^32^ | Biliopancreatic diversion | Case series | 649 | NR | Consecutive patients
FRIEDMAN 1992^42^ | Biliopancreatic diversion | Case series | 747 | 1976-1990 | Assembly method not reported
FRIEDMAN 1992^78^ | Biliopancreatic diversion | Case series | 747 | 1976-1990 | Assembly method not reported
FRIEDMAN 1995^43^ | Biliopancreatic diversion | Cohort | 1136 | 1976-1994 | Consecutive patients
FRIEDMAN 1996^79^ | Gastric bypass, Biliopancreatic diversion | Case series | 152 | Pre 1995 | Other (literature review)
GANDRY 2006^80^ | Adjustable gastric banding | Case report | 1 | 2004 | Not applicable (not cohort study)
GAUDRY 2004^55^ | Adjustable gastric banding | Case report | 1 | NR | Not applicable (not cohort study)
GEORGE 2005^45^ | Biliopancreatic diversion | Case report | 1 | NR | Not applicable (not cohort study)
GERRITS 2003^35^ | Biliopancreatic diversion | Case series | 40 | 1997-1998 | Consecutive patients
GRANGE 1994^52^ | Gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
GRANSTROM 1990^81^ | Adjustable gastric banding | Case report | 1 | NR | Not applicable (not cohort study)
GRAUBARD 1988^69^ | Biliopancreatic diversion | Case report | 1 | NR | Not applicable (not cohort study)
GUREWITSCH 1996^53^ | Gastric gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
HADDOW 1986^49^ | Gastric gastric bypass | Case series | 3 | 1980-1984 | Assembly method not reported
HALL 1990^82^ | Gastric bypass, Vertical banded gastroplasty | Controlled trial | 310 | NR-1984 | Clinical trial
HODA 2002^83^ | Adjustable gastric banding | Case series | 2 | | Not applicable (not cohort study)
HUERTA 2002^47^ | Biliopancreatic diversion | Case report | 1 | | Not applicable (not cohort study)
JESTER 1997^62^ | Gastric bypass, other surgery | Case series | 100 | NR | Convenience sample
KAKARLA 2005^66^ | Gastric bypass | Case series | 2 | NR | Not applicable (not cohort study)
KRAL 2006^64^ | Biliopancreatic diversion | Cohort | 113 | 1982-2001 | Assembly method not reported
LOAR 2005^68^ | Gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
MARCEAU 2004^27^ | Biliopancreatic diversion | Cohort | 783 | 1984-2000 | Consecutive patients
MARTENS 1990^51^ | Gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
MARTIN 1988^48^ | Gastric bypass | Case series | 87 | NR | Selected sample
MARTIN 1997^57^ | Adjustable gastric banding | Case series | 98 | NR | Consecutive patients
MARTIN 2000^31^ | Adjustable gastric banding | Case series | 265 | 1990-1998 | Clinical trial
MOOR 2004^67^ | Gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
PRINTEN 1982^40^ | Gastric bypass | Case series | 45 | NR | Assembly method not reported
RAMIREZ 1995^84^ | Vertical banded gastroplasy | Case report | 1 | NR | Not applicable (not cohort study)
RAND 1989^59^ | Gastric bypass | Case series | 18 | NR | Assembly method not reported
RICHARDS 1987^85^ | Gastric bypass | Case control | 243 | 1979-1983 | Selected sample
SHEINER 2004^28^ | Gastric bypass, Adjustable gastric banding, Biliopancreatic diversion, Vertical banded gastroplasty | Cohort | 159210 | 1988-2002 | Selected sample
SHEINER 2006^29^ | Gastric bypass, Adjustable gastric banding | Cohort | 8014 | 1988-2002 | Selected sample
SKULL 2004^56^ | Adjustable gastric banding | Cohort | 44 | 1996-NR | Consecutive patients
SMETS 2006^46^ | Biliopancreatic diversion | Case report | 1 | NR | Not applicable (not cohort study)
STRAUSS 2001^63^ | Gastric bypass | Case series | 7 | 1983-1999 | Selected sample
TSENOV 1994^86^ | Biliopancreatic diversion | Case report | 1 | MISSING | Not applicable (not cohort study)
WEINER 2003^33^ | Adjustable gastric banding | Case series | 678 | 1994-2002 | Consecutive patients
WEISS 2001^54^ | Adjustable gastric banding | Case series | 215 | 1996-2000 | Consecutive patients
WEISSMAN 1995^87^ | Gastric bypass | Case report | 1 | NR | Not applicable (not cohort study)
WITTGROVE 1998^34^ | Gastric bypass | Cohort | 41 | early 1980's-1998 | Volunteers, response to media