# Appendix C. Data Collection Form

To see the Data Collection Form, please select the link below. This link will take you to a PDF version of the form.

Data Collection Form