# Appendix B. Search Strategies

BARIATRIC SURGERY & PREGNANCY - SEARCH METHODOLOGIES

SEARCH #1 (Performed 11/3/2006):

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed - 1985-2006 (November)

SEARCH STRATEGY:

bariatric surgery OR bariatric*[tiab] OR gastric bypass OR gastric band OR gastric bands OR laparoscopic adjustable band OR laparoscopic adjustable bands OR lap band OR lap bands OR lap-band OR lap-bands OR sleeve gastrectom* OR intragastric balloon* OR intra-gastric balloon* OR gastric stimulat* OR biliopancreat* diversion* OR duodenal switch* OR scopinaro switch* OR gastroplast* OR gastric restrictive surgery OR jejunal ileal bypass* OR jejunal-ileal bypass* OR jejunoileal bypass* OR obesity surgery OR weight loss surgery OR weight reduction surgery OR weight reduction operation* OR (intestinal bypass* OR surgical management OR surgical treatment OR gastric surgery) and (obesity OR obese) OR gastric banding OR vertical banded gastroplasty

AND

fertility OR contraception OR pregnan* OR prenatal OR cesarean OR mother OR neonate* OR obstetric*

TOTAL NUMBER OF ITEMS RETRIEVED - 804

SEARCH #2 (Performed 11/6/2006):

DATABASES SEARCHED:

PubMed

SEARCH STRATEGY:

“Related Articles” search on the following article:

O'Brien PE, Dixon JB, Laurie C, Skinner S, Proietto J, McNeil J, Strauss B, Marks S, Schachter L, Chapman L, et al. Treatment of mild to moderate obesity with laparoscopic adjustable gastric banding or an intensive medical program: a randomized trial. Ann Intern Med 2006 May 2;144(9):625–33.

TOTAL NUMBER OF ITEMS RETRIEVED - 131

SEARCH #3 (Performed 11/9/2006):

DATABASES SEARCHED:

Cochrane Database of Systematic Reviews - 1985-2006

Cochrane Database of Abstracts of Reviews of Effects - All years

SEARCH STRATEGY:

(bariatric surgery or bariatric$ OR gastric bypass OR gastric band OR gastric bands OR laparoscopic adjustable band OR laparoscopic adjustable bands OR lap band OR lap bands OR lap-band OR lap-bands OR sleeve gastrectom$ OR intragastric balloon$ OR intra-gastric balloon$ OR gastric stimulat$ OR biliopancreat$ diversion$ OR duodenal switch$ OR scopinaro switch$ OR gastroplast$ OR gastric restrictive surgery OR jejunal ileal bypass$ OR jejunal-ileal bypass$ OR jejunoileal bypass$ OR obesity surgery OR weight loss surgery OR weight reduction surgery OR weight reduction operation OR ((intestinal bypass$ OR surgical management OR surgical treatment OR gastric surgery) AND (obesity OR obese)) OR gastric banding OR vertical banded gastroplasty).mp. [mp=ti, ot, ab, sh, hw, kw, tx, ct]

AND

fertility OR contraception OR pregnan$ OR prenatal OR cesarean OR mother OR neonat$e OR pregnancy complications OR pregnancy outcome OR obstetric$.mp.

TOTAL NUMBER OF ITEMS RETRIEVED - 37

SEARCH #4 (Performed 11/16/2006):

DATABASES SEARCHED:

Embase - 1985-2006

SEARCH STRATEGY:

bariatric surgery! OR gastric banding OR gastric bypass OR stomach bypass OR gastric(2n)bypass? OR (laparoscopic surgery AND band?) OR lap?(2w)band? OR gastrectom?(2n)sleeve? OR intragastric(2n)balloon? OR intra(1w)gastric(2n)balloon? OR gastric(2n)stimulat? OR biliopancreatic()bypass OR duoden?(2n)switch? OR scopinaro(2n)switch? OR biliopancreatic(2n)diver? OR gastroplasty OR gastric(2w)restrict? OR jejunal(2w)ileal(f)bypass? OR (obesity/ti,de AND (surgery/de,ti OR operation)) OR (weight reduction AND (surgery/ti,de OR operation)) OR ((intestin?(2n)bypass? OR surgical management OR surgical approach OR surgical(2n)risk? OR surgery(2n)risk? OR stomach surgery) AND obes?) OR (surgery/ti,de AND obes?)

AND

fertility! OR pregnancy! OR pregnancy complication! OR pregnan?/ti OR contracept? OR prenatal development! OR prenatal disorder! OR prenatal mortality OR prenatal/ti OR neonatal OR newborn OR cesarean section? OR perinatal development OR perinatal mortality OR perinatal morbidity OR perinatal/ti

TOTAL NUMBER OF ITEMS RETRIEVED - 495