# Appendix A. Technical Expert Panel Members and Peer Reviewers

## Technical Expert Panel Members

Name | Affiliation
Edward Livingston, MD | University of Texas, Southwestern Medical Center at Dallas
Carol Major, MD | University of California at Irvine Medical Center
John Morton, MD | Stanford University Medical Center
Nanette Santoro, MD | Albert Einstein College of Medicine

## Peer Reviewers

Name | Affiliation
Alison Avenell, MD | University of Aberdeen, Health Services Research Unit
Susan Meikle, MD | National Institute of Child Health and Human Development
Claudia Steiner, MD | Agency for Healthcare Research and Quality