# Appendixes

Appendix A. Technical Expert Panel Members and Peer Reviewers

Appendix B. Search Strategies

Appendix C. Data Collection Form

Appendix D. Evidence Table

Appendix E. Rejected Titles