# Appendixes

Appendix A. Search Strategy

Appendix B. Sample Data Collection Forms

Appendix C. Evidence Tables

Appendix D. List of Excluded Studies

Appendix E. Acknowledgments