# Appendix E. Acknowledgments

This study was supported by Contract 290-02-0016 from the Agency for Healthcare Research and Quality (AHRQ), Task No.1, Work Assignment 8. We acknowledge the continuing support of Beth Collins Sharp, Ph.D., R.N. Acting Director of the AHRQ Evidence-Based Practice Center (EPC) Program and the AHRQ Task Order Officer for this project.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina (UNC). From UNC, we thank EPC Co-Director, Timothy S. Carey, MD, MPH; EPC Literature Search Specialist, B. Lynn Whitener, PhD. We express our gratitude to Loraine Monroe, EPC word processing specialist, and Tammeka Swinson Evans, BA, research specialist, at RTI International.

## Technical Expert Panel

We extend our appreciation to the members of our Technical Expert Panel (TEP), who provided advice and input during our research process. The RTI-UNC EPC team solicited the views of TEP members from the beginning of the project. TEP members also provided insights into and reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members participated in refining the analytic framework and key questions and discussing the preliminary assessment of the literature, including inclusion/exclusion criteria, and also provided input on the information and categories, including evidence tables. The TEP was both a substantive resource and a “sounding board” throughout the study. It was also the body from which expertise was formally sought at several junctions. TEP members are listed below (* also a peer review):

- Erica Gunderson, PhD
- Investigator
- Division of Research (DOR)
- Kaiser Permanente Northern California

- Naomi Stotland, MD
- Assistant Professor
- Department of Obstetrics and Gynecology
- University of California, San Francisco

- Calvin Hobel, MD
- Vice Chair
- Department of Obstetrics and Gynecology
- Cedars-Sinai Medical Center

- Lorraine Walker, RN, EdD, FAAN*
- Professor
- School of Nursing
- University of Texas at Austin

- Esa M. Davis, M.D., M.P.H.*
- Assistant Professor
- Department of Family Medicine
- Case Western Reserve University School of Medicine

- Mary H. Hager, PhD, RD, FADA*
- Senior Manager, Regulatory Affairs Policy Initiatives and Advocacy
- American Dietetic Association

## Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. External reviewers comprised clinicians, researchers, representatives of professional societies, and potential users of the report. We would also like to extend our appreciation to David Atkins, MD and other reviewers from AHRQ for contributing peer review comments. Our peer review panel also includes three members of the TEP. Peer review was a separate duty for these individuals and not part of their commitment as TEP members. All are active professionals in the field. The peer reviewers were asked to provide comments on the content, structure, and format of the evidence report and to complete a checklist. The peer reviewers' comments and suggestions formed the basis of our revisions to the evidence report. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

- Barbara Hackley, MS, RN, CNM
- Associate Professor
- Yale School of Nursing

- Denise Sofka, RD, MPH
- Project Officer
- Maternal and Child Health Bureau
- Department of Health and Human. Services

- Mary Hediger, PhD
- Epidemiologist
- Epidemiology (EPI) Branch/DESPR
- National Institute of Child Health and Human Development
- National Institutes of Health

- Barbara Abrams, DrPH, RD
- Professor
- University of California, Berkeley
- School of Public Health

- Emily Oken, MD, MPH
- Physician
- Department of Ambulatory Care and Prevention
- Harvard Medical School and Harvard Pilgrim Health Care

- Mary Dallavalle M.S., RD, LD
- Nutrition Education Specialist
- Special Supplemental Nutrition Program for Women, Infants, and Children
- (WIC Program)

- Kathleen Rasmussen, Sc.D.
- Professor of Nutrition
- Division of Nutritional Science
- International Professor of Nutritional Science
- College of Agriculture and Life Sciences
- Cornell University

- Patricia Fontaine MD, MS
- Associate Professor
- Department of Family Medicine
- University of Minnesota Medical School