# Appendix D. List of Excluded Studies

## Exclusion Codes

Code | Criteria | N
X-1 | Article is not concerned with topics relevant to maternal weight gain or the measurement of body fat | 80
X-2 | Wrong publication type (e.g. letter, commentary or editorial) | 32
X-4 | n < 40 for comparisons including cohort studies | 10
X-5 | n < 100 for case-series | 2
X-6 | Not published in english | 0
X-7 | Wrong publication type (e.g. letter, commentary or editorial) | 2
X-8 | Wrong design - please explain | 23
X-9 | Includes only a population w/ a pre-existing condition - please list condition | 18
X-10 | 100% multi-fetal | 2
X-12 | Study not conducted in a developed nation? | 21
X-14 | Not related to key questions | 74
X-17 | Pre-pregnancy weight or BMI is not in article | 36

### References

1 From the Centers for Disease Control. Pregnancy risks determined from birth certificate data—United States, 1989. J Am Med Assoc 1992;268(14):1831–2. X2
2 Pregnancy risks determined from birth certificate data—United States, 1989. MMWR Morb Mortal Wkly Rep 1992;41(30):556–63. X1
3 From the Centers for Disease Control and Prevention. Pregnancy-related behaviors among migrant farm workers—four states, 1989-1993. J Am Med Assoc 1997;277(19):1512. X2
4 Midwifery and childbirth news. Midwifery Today 2006(79):60–60. X1
5 Recommended gestational weight gain linked to childhood obesity. Contemp OB/GYN 2007;52(5):19–19. X2
6 New in review. Periodicals. J Am Diet Assoc 2007;107(3):512–517. X1
7 Abrams B. Prenatal weight gain and postpartum weight retention: a delicate balance. Am J Pub Health. 1993;83(8):1082-1084. X2, B. [pmid: 8342710].
8 Abrams B, Carmichael S, Selvin S. Factors associated with the pattern of maternal weight gain during pregnancy. Obstet Gynecol. 1995;86(2):170-6. X8. [pmid: 7617345].
9 Abrams B, Parker JD. Maternal weight gain in women with good pregnancy outcome. Obstet Gynecol. 1990;76(1):1-7. X17. [pmid: 2359553].
10 Achadi EL, Hansell MJ, Sloan NL, Anderson MA. Women's nutritional status, iron consumption and weight gain during pregnancy in relation to neonatal weight and length in West Java, Indonesia. Int J Gynaecol Obstet. 1995;48(Suppl):S103-19. X12. [pmid: 7672170].
11 Akbay E, Tiras MB, Yetkin I, Toruner F, Ersoy R, Uysal S, Ayvaz G. Insulin secretion and insulin sensitivity in normal pregnancy and gestational diabetes mellitus. Gynecol Endocrinol. 2003;17(2):137-42. X1. [pmid: 12737675].
12 Albers LL. Clues to positive birth outcomes in New Mexico. J Nurse Midwifery. 1994;39(4):273-7. X14. [pmid: 7965194].
13 Albers LL, Greulich B, Peralta P. Body mass index, midwifery intrapartum care, and childbirth lacerations. J Midwifery Womens Health. 2006;51(4):249-53. X14. [pmid: 16814218].
14 Althuizen E, van Poppel MN, Seidell JC, van der Wijden C, van Mechelen W. Design of the New Life(style) study: a randomised controlled trial to optimise maternal weight development during pregnancy. [ISRCTN85313483]. BMC Public Health. 2006;6:168. X8. [pmid: 16800869].
15 Anderson NE, Smiley DV, Flick LH, Lewis CY. Missouri Rural Adolescent Pregnancy Project (MORAPP). Public Health Nurs. 2000;17(5):355-362. X14. [pmid: 11012998].
16 Artal R, Catanzaro RB, Gavard JA, Mostello DJ, Friganza JC. A lifestyle intervention of weight-gain restriction: diet and exercise in obese women with gestational diabetes mellitus. Appl Physiol Nutr Metab. 2007;32(3):596-601. X2. [pmid: 17510701].
17 Ayustawati, Matsubara S, Minakami H, Ohkuchi A, Izumi A, Sato I. Symphysis-fundus height and weight gain pattern in Japanese women with twin pregnancies. J Reprod Med. 2003;48(4):277-82. X10. [pmid: 12746992].
18 Babinszki A, Kerenyi T, Torok O, Grazi V, Lapinski RH, Berkowitz RL. Perinatal outcome in grand and great-grand multiparity: effects of parity on obstetric risk factors. Am J Obstet Gynecol. 1999;181(3):669-74. X14. [pmid: 10486482].
19 Bainbridge J. Lingering pregnancy fat puts women in danger. Br J Midwifery. 2006;14(11):644-644. X2.
20 Barker DJ. Fetal programming of coronary heart disease. Trends Endocrinol Metab. 2002;13(9):364-8. X2. [pmid: 12367816].
21 Barnett E. Race differences in the proportion of low birth weight attributable to maternal cigarette smoking in a low-income population. Am J Health Promot. 1995;10(2):105-110. X1. [pmid: 10160043].
22 Barry H. Does abnormal weight gain in pregnancy predict poor outcome?. Evidence-Based Pract. 1998;1(4):9-10. insert 2p. X2.
23 Bar-Zohar D, Azem F, Klausner J, Abu-Abeid S. Pregnancy after laparoscopic adjustable gastric banding: perinatal outcome is favorable also for women with relatively high gestational weight gain. Surg Endosc. 2006;20(10):1580-3. X9. [pmid: 16902748].
24 Behrman CA, Hediger ML, Scholl TO, Arkangel CM. Nausea and vomiting during teenage pregnancy: effects on birth weight. J Adolesc Health Care. 1990;11(5):418-22. X14. [pmid: 2211275].
25 Berenson AB, Wiemann CM, Rowe TF, Rickert VI. Inadequate weight gain among pregnant adolescents: risk factors and relationship to infant birth weight. Am J Obstet Gynecol. 1997;176(6):1220-4. discussion 1224–7. X17. [pmid: 9215177].
26 Bergmann MM, Flagg EW, Miracle-McMahill HL, Boeing H. Energy intake and net weight gain in pregnant women according to body mass index (BMI) status. Int J Obes Relat Metab Disord. 1997;21(11):1010-7. X14. [pmid: 9368824].
27 Bergsjo P, Bakketeig LS, Lindmark G. Maternal smoking does not affect fetal size as measured in the mid-second trimester. Acta Obstet Gynecol Scand. 2007;86(2):156-60. X1. [pmid: 17364277].
28 Black J. Re: Urinalysis and weighing at all antenatal visits. Aust N Z J Obstet Gynaecol. 2005;45(6):541. X2. [pmid: 16401234].
29 Bo S, Marchisio B, Volpiano M, Menato G, Pagano G. Maternal low birth weight and gestational hyperglycemia. Gynecol Endocrinol. 2003;17(2):133-6. X14. [pmid: 12737674].
30 Bodnar LM, Ness RB, Markovic N, Roberts JM. The risk of preeclampsia rises with increasing prepregnancy body mass index. Ann Epidemiol. 2005;15(7):475-482. X1. [pmid: 16029839].
31 Bodnar LM, Siega-Riz AM, Cogswell ME. High prepregnancy BMI increases the risk of postpartum anemia. Obes Res. 2004;12(6):941-8. X1. [pmid: 15229333].
32 Boney CM, Verma A, Tucker R, Vohr BR. Metabolic syndrome in childhood: association with birth weight, maternal obesity, and gestational diabetes mellitus. Pediatrics. 2005;115(3):e290-6. X14. [pmid: 15741354].
33 Brawarsky P, Stotland NE, Jackson RA, Fuentes-Afflick E, Escobar GJ, Rubashkin N, Haas JS. Pre-pregnancy and pregnancy-related factors and the risk of excessive or inadequate gestational weight gain. Int J Gynaecol Obstet. 2005;91(2):125-31. X14, B. [pmid: 16202415].
34 Bronsky J, Karpisek M, Bronska E, Pechova M, Jancikova B, Kotolova H, Stejskal D, Prusa R, Nevoral J. Adiponectin, adipocyte fatty acid binding protein, and epidermal fatty acid binding protein: proteins newly identified in human breast milk. Clin Chem. 2006;52(9):1763-70. X12. [pmid: 16873294].
35 Brost BC, Goldenberg RL, Mercer BM, Iams JD, Meis PJ, Moawad AH, Newman RB, Miodovnik M, Caritis SN, Thurnau GR, Bottoms SF, Das A, McNellis D. The Preterm Prediction Study: association of cesarean delivery with increases in maternal weight and body mass index. Am J Obstet Gynecol. 1997;177(2):333-7. discussion 337–41. X1. [pmid: 9290448].
36 Brown JE, Kaye SA, Folsom AR. Parity-related weight change in women. Int J Obes Relat Metab Disord. 1992;16(9):627-31. X1. [pmid: 1328085].
37 Brown JE, Mahan CS. Weight gain and pregnancy outcome. Am J Obstet Gynecol. 1996;175(5):1396-7. X2. [pmid: 8942531].
38 Buchanan TA, Xiang A, Kjos SL, Lee WP, Trigo E, Nader I, Bergner EA, Palmer JP, Peters RK. Gestational diabetes: antepartum characteristics that predict postpartum glucose intolerance and type 2 diabetes in Latino women. Diabetes. 1998;47(8):1302-10. X9. [pmid: 9703332].
39 Burrowes JD. Nutrition for a lifetime. Nutr Today. 2006;41(6):267-273. X8.
40 Buschman NA, Foster G, Vickers P. Adolescent girls and their babies: achieving optimal birthweight. Gestational weight gain and pregnancy outcome in terms of gestation at delivery and infant birth weight: a comparison between adolescents under 16 and adult women. Child Care Health Dev. 2001;27(2):163-71. X14. [pmid: 11251614].
41 Butte NF. Energy requirements during pregnancy and consequences of deviations from requirement on fetal outcome. Nestle Nutr Workshop Ser Pediatr Program 2005(55):49–67; discussion 67–71. X8
42 Butte NF, Wong WW, Treuth MS, Ellis KJ, O'Brian Smith E. Energy requirements during pregnancy based on total energy expenditure and energy deposition. Am J Clin Nutr. 2004;79(6):1078-87. X1. [pmid: 15159239].
43 Calfee EF, Rust OA, Bofill JA, Ross EL, Morrison JC. Maternal hypoglycemia: is it associated with adverse perinatal outcome?. J Perinatol. 1999;19(5):379-82. X14. [pmid: 10685261].
44 Carmichael S, Abrams B, Selvin S. The pattern of maternal weight gain in women with good pregnancy outcomes. Am J Public Health. 1997;87(12):1984-8. B, X14. [pmid: 9431288].
45 Carpenter MW, Sady SP, Sady MA, Haydon B, Coustan DR, Thompson PD. Effect of maternal weight gain during pregnancy on exercise performance. J Appl Physiol. 1990;68(3):1173-6. X1. [pmid: 2341342].
46 Casanueva E, Rosello-Soberon ME, De-Regil LM, Arguelles Mdel C, Cespedes MI. Adolescents with adequate birth weight newborns diminish energy expenditure and cease growth. J Nutr. 2006;136(10):2498-501. X14. [pmid: 16988116].
47 Catalano PM. Management of obesity in pregnancy. Obstet Gynecol. 2007;109(2 Part 1):419-433. X8. [pmid: 17267845].
48 Caulfield LE, Witter FR, Stoltzfus RJ. Determinants of gestational weight gain outside the recommended ranges among black and white women. Obstet Gynecol. 1996;87(5 Pt 1):760-6. B, X8. [pmid: 8677082].
49 Cazano C, Russell BK, Brion LP. Size at birth in an inner-city population. Am J Perinatol. 1999;16(10):543-8. X14. [pmid: 10874992].
50 Chez RA. Weight gain during pregnancy. Am J Pub Health;76(12):1390–1391. X7
51 Clapp JF 3rd, Kim H, Burciu B, Schmidt S, Petry K, Lopez B. Continuing regular exercise during pregnancy: effect of exercise volume on fetoplacental growth. Am J Obstet Gynecol. 2002;186(1):142-7. X14. [pmid: 11810100].
52 Cliver SP, Goldenberg RL, Cutter GR, Hoffman HJ, Copper RL, Gotlieb SJ, Davis RO. The relationships among psychosocial profile, maternal size, and smoking in predicting fetal growth retardation. Obstet Gynecol. 1992;80(2):262-7. X14. [pmid: 1635741].
53 Cogswell ME, Scanlon KS, Fein SB, Schieve LA. Medically advised, mother's personal target, and actual weight gain during pregnancy. Obstet Gynecol. 1999;94(4):616-22. X14, B. [pmid: 10511369].
54 Colletto GM, Segre CA. Lack of effect of maternal body mass index on anthropometric characteristics of newborns in twin gestations. Genet Mol Res. 2005;4(1):47-54. X1. [pmid: 15841435].
55 Conti J, Abraham S, Taylor A. Eating behavior and pregnancy outcome. J Psychosom Res. 1998;44(34):465-77. X17. [pmid: 9587889].
56 Copper RL, DuBard MB, Goldenberg RL, Oweis AI. The relationship of maternal attitude toward weight gain to weight gain during pregnancy and low birth weight. Obstet Gynecol. 1995;85(4):590-5. X14. [pmid: 7898839].
57 Cordero L, Hines S, Shibley KA, Landon MB. Perinatal outcome for women in prison. J Perinatol. 1992;12(3):205-9. X9. [pmid: 1432273].
58 Covington DL, Peoples-Sheps MD, Buescher PA, Bennett TA, Paul MV. An evaluation of an adolescent prenatal education program. Am J Health Behav. 1998;22(5):323-333. X14.
59 Cox S. Weight gain during pregnancy. J Midwifery Womens Health. 2003;48(3):229-30. X7. [pmid: 12764310].
60 Cundy T, Gamble G, Manuel A, Townend K, Roberts A. Determinants of birth-weight in women with established and gestational diabetes. Aust N Z J Obstet Gynaecol. 1993;33(3):249-54. X9. [pmid: 8304885].
61 Czeizel AE, Dudas I, Dobo M, Pal M. Maternal weight gain and birth weight. Acta Paediatr Hung. 1992;32(2):91-100. X12. [pmid: 1389323].
62 Dabbs WN. Got milk?. J Miss State Med Assoc. 2004;45(4):102-5. X1. [pmid: 15114795].
63 D'Alfonso A, Iovenitti P, Carta G. Urinary disorders during pregnancy and postpartum: our experience. Clin Exp Obstet Gynecol. 2006;33(1):23-5. X17. [pmid: 16761533].
64 Davies K, Wardle J. Body image and dieting in pregnancy. J Psychosom Res. 1994;38(8):787-99. X14. [pmid: 7722959].
65 Dawes MG, Green J, Ashurst H. Routine weighing in pregnancy. Br Med J. 1992;304(6825):487-9. X1. [pmid: 1547424].
66 Dawes MG, Grudzinskas JG. Patterns of maternal weight gain in pregnancy. Br J Obstet Gynaecol. 1991;98(2):195-201. X14. [pmid: 2004057].
67 de Groot LC. High maternal body weight and pregnancy outcome. Nutr Rev. 1999;57(2):62-4. X2. [pmid: 10079705].
68 de Jong CL, Gardosi J, Baldwin C, Francis A, Dekker GA, van Geijn HP. Fetal weight gain in a serially scanned high-risk population. Ultrasound Obstet Gynecol. 1998;11(1):39-43. X1. [pmid: 9511194].
69 Di Cianni G, Benzi L, Bottone P, Volpe L, Orsini P, Murru S, Casadidio I, Clemente F, Navalesi R. Neonatal outcome and obstetric complications in women with gestational diabetes: effects of maternal body mass index. Int J Obes Relat Metab Disord. 1996;20(5):445-9. X17. [pmid: 8696423].
70 Di Cianni G, Volpe L, Ghio A, Lencioni C, Cuccuru I, Benzi L, Del Prato S. Maternal metabolic control and perinatal outcome in women with gestational diabetes mellitus treated with Lispro or Aspart Insulin: comparison with regular insulin. Diabet Care. 2007;30(4):e11-e11. X1.
71 Di Cianni G, Volpe L, Lencioni C, Miccoli R, Cuccuru I, Ghio A, Chatzianagnostou K, Bottone P, Teti G, Del Prato S, Benzi L. Prevalence and risk factors for gestational diabetes assessed by universal screening. Diabet Res Clin Pract. 2003;62(2):131-7. X14.
72 DiPietro JA, Millet S, Costigan KA, Gurewitsch E, Caulfield LE. Psychosocial influences on weight gain attitudes and behaviors during pregnancy. J Am Diet Assoc. 2003;103(10):1314-1319. X1. [pmid: 14520249].
73 Dixon JB, Dixon ME, O'Brien PE. Birth outcomes in obese women after laparoscopic adjustable gastric banding. Obstet Gynecol. 2005;106(5 Pt 1):965-72. X9. [pmid: 16260513].
74 Dubois L, Girard M. Early determinants of overweight at 4.5 years in a population-based longitudinal study. Int J Obes (Lond). 2006;30(4):610-7. X1. [pmid: 16570091].
75 Durnwald CP, Ehrenberg HM, Mercer BM. The impact of maternal obesity and weight gain on vaginal birth after cesarean section success. Am J Obstet Gynecol. 2004;191(3):954-7. X14. [pmid: 15467571].
76 Ehrenberg HM, Dierker L, Milluzzi C, Mercer BM. Low maternal weight, failure to thrive in pregnancy, and adverse pregnancy outcomes. Am J Obstet Gynecol. 2003;189(6):1726-30. X17. [pmid: 14710105].
77 Ehrenberg HM, Durnwald CP, Catalano P, Mercer BM. The influence of obesity and diabetes on the risk of cesarean delivery. Am J Obstet Gynecol. 2004;191(3):969-74. X1. [pmid: 15467574].
78 Ellard GA, Johnstone FD, Prescott RJ, Ji-Xian W, Jian-Hua M. Smoking during pregnancy: the dose dependence of birthweight deficits. Br J Obstet Gynaecol. 1996;103(8):806-13. X1. [pmid: 8760712].
79 Ellison GT, Holliday M. The use of maternal weight measurements during antenatal care. A national survey of midwifery practice throughout the United Kingdom. J Eval Clin Pract. 1997;3(4):303-17. X1. [pmid: 9456430].
80 Erez-Weiss I, Erez O, Shoham-Vardi I, Holcberg G, Mazor M. The association between maternal obesity, glucose intolerance and hypertensive disorders of pregnancy in nondiabetic pregnant women. Hypertens Pregnancy. 2005;24(2):125-36. X12. [pmid: 16036397].
81 Eriksson JG. Early growth and adult health outcomes—lessons learned from the Helsinki Birth Cohort Study. Matern Child Nutr. 2005;1(3):149-54. X1. [pmid: 16881894].
82 Evans KC, Evans RG, Royal R, Esterman AJ, James SL. Effect of caesarean section on breast milk transfer to the normal term newborn over the first week of life. Arch Dis Child Fetal Neonatal Ed. 2003;88(5):F380-2. X1. [pmid: 12937041].
83 Farr SL, Jamieson DJ, Rivera HV, Ahmed Y, Heilig CM. Risk factors for cesarean delivery among Puerto Rican women. Obstet Gynecol. 2007;109(6):1351-1357. X14. [pmid: 17540807].
84 Fell DB, Joseph KS, Dodds L, Allen AC, Jangaard K, Van den Hof M. Changes in maternal characteristics in Nova Scotia, Canada from 1988 to 2001. Can J Public Health. 2005;96(3):234-8. X8. [pmid: 15913093].
85 Forsum E. Energy requirements during pregnancy: old questions and new findings. Am J Clin Nutr. 2004;79(6):933-4. X2. [pmid: 15159221].
86 Fowles ER. Comparing pregnant women's nutritional knowledge to their actual dietary intake. Am J Matern Child Nurs. 2002;27(3):171-177. X1.
87 Fowles ER, Walker LO. Correlates of dietary quality and weight retention in postpartum women. J Comm Health Nurs. 2006;23(3):183-197. X17.
88 Frederick IO, Rudra CB, Miller RS, Foster JC, Williams MA. Adult weight change, weight cycling, and prepregnancy obesity in relation to risk of preeclampsia. Epidemiology. 2006;17(4):428-34. X1. [pmid: 16755262].
89 Galvez M, Myles TD. Teenage pregnancy in the Texas Panhandle. J Rural Health. 2005;21(3):259-62. X14. [pmid: 16092301].
90 Gillman MW. Developmental origins of health and disease. N Engl J Med. 2005;353(17):1848-50. X1. [pmid: 16251542].
91 Gillman MW, Rich-Edwards JW, Huh S, Majzoub JA, Oken E, Taveras EM, Rifas-Shiman SL. Maternal corticotropin-releasing hormone levels during pregnancy and offspring adiposity. Obesity (Silver Spring). 2006;14(9):1647-53. X14. [pmid: 17030976].
92 Giovannini M, Radaelli G, Banderali G, Riva E. Low prepregnant body mass index and breastfeeding practices. J Hum Lact. 2007;23(1):44-51. X1. [pmid: 17293550].
93 Giuliani A, Tamussino K, Basver A, Haas J, Petru E. The impact of body mass index and weight gain during pregnancy on puerperal complications after spontaneous vaginal delivery. Wien Klin Wochenschr. 2002;114(1011):383-6. X17. [pmid: 12708091].
94 Goldenberg RL, Iams JD, Mercer BM, Meis P, Moawad A, Das A, Copper R, Johnson F. What we have learned about the predictors of preterm birth. Semin Perinatol. 2003;27(3):185-93. X1. [pmid: 12889585].
95 Gonen O, Rosen DJ, Dolfin Z, Tepper R, Markov S, Fejgin MD. Induction of labor versus expectant management in macrosomia: a randomized study. Obstet Gynecol. 1997;89(6):913-7. X1. [pmid: 9170464].
96 Goodman MM, Clarke JA, Jehne C. A case for revising the ‘weight gain during pregnancy’ guidelines for Australian women. Aust N Z J Obstet Gynaecol. 1992;32(2):129-32. X1. [pmid: 1520197].
97 Gray-Donald K, Robinson E, Collier A, David K, Renaud L, Rodrigues S. Intervening to reduce weight gain in pregnancy and gestational diabetes mellitus in Cree communities: an evaluation. Can Med Assoc J. 2000;163(10):1247-51. X14. [pmid: 11107459].
98 Grisaru-Granovsky S, Eitan R, Algur N, Schimmel MS, Diamant YZ, Samueloff A. Maternal and umbilical cord serum leptin concentrations in small-for-gestational-age and in appropriate-for-gestational-age neonates: a maternal, fetal, or placental contribution?. Biol Neonate. 2003;84(1):67-72. X4. [pmid: 12890940].
99 Groth S. Are the Institute of Medicine recommendations for gestational weight gain appropriate for adolescents?. J Obstet Gynecol Neonatal Nurs. 2007;36(1):21-7. X17.
100 Gunderson EP. Nutrition during pregnancy for the physically active woman. Clin Obstet Gynecol. 2003;46(2):390-402. X14. [pmid: 12808389].
101 Gunderson EP, Murtaugh MA, Lewis CE, Quesenberry CP, West DS, Sidney S. Excess gains in weight and waist circumference associated with childbearing: The Coronary Artery Risk Development in Young Adults Study (CARDIA). Int J Obes Relat Metab Disord. 2004;28(4):525-35. X14. [pmid: 14770188].
102 Gunes T, Koklu E, Ozturk MA. Maternal and cord serum lipid profiles of preterm infants with respiratory distress syndrome. J Perinatol. 2007;27(7):415-21. X12. [pmid: 17554390].
103 Gutbrod T, Wolke D, Soehne B, Ohrt B, Riegel K. Effects of gestation and birth weight on the growth and development of very low birthweight small for gestational age infants: a matched group comparison. Arch Dis Child Fetal Neonatal Ed. 2000;82(3):F208-14. X1. [pmid: 10794788].
104 Gutierrez YM. Cultural factors affecting diet and pregnancy outcome of Mexican American adolescents. J Adolesc Health. 1999;25(3):227-37. X8. [pmid: 10475499].
105 Haakstad LA, Voldner N, Henriksen T, Bo K. Physical activity level and weight gain in a cohort of pregnant Norwegian women. Acta Obstet Gynecol Scand. 2007;86(5):559-64. X14. [pmid: 17464584].
106 Haas AV. Preventing complications with nutrition. Midwifery Today Int Midwife 2003(67):40–1. X2
107 Harris H. Is fat a pregnancy issue?. Pract Midwife. 1998;1(6):20-2. X8. [pmid: 9735818].
108 Harris HE, Ellison GT. Practical approaches for estimating prepregnant body weight. J Nurse Midwifery. 1998;43(2):97-101. X14. [pmid: 9581094].
109 Harris HE, Ellison GTH, Richter LM, De Wet T, Levin J. Are overweight women at increased risk of obesity following pregnancy?. Br J Nutr. 1998;79(6):489-494. X14. [pmid: 9771335].
110 Heilemann MV, Lee KA, Stinson J, Koshar JH, Goss G. Acculturation and perinatal health outcomes among rural women of Mexican descent. Res Nurs Health. 2000;23(2):118-25. X17. [pmid: 10782870].
111 Helms E, Coulson CC, Galvin SL. Trends in weight gain during pregnancy: a population study across 16 years in North Carolina. Am J Obstet Gynecol. 2006;194(5):e32-4. X17. [pmid: 16647894].
112 Herman AA, Yu KF. Adolescent age at first pregnancy and subsequent obesity. Paediatr Perinat Epidemiol. 1997;11(Suppl 1):130-41. X14. [pmid: 9018722].
113 Herrera-Perdigon J, Hopkins E, Marcalle M, Brooten D, Youngblut JM, Lizardo ML. Weight gain in high-risk pregnant women: comparison by primary diagnosis and type of care. Clin Excell Nurse Pract. 2005;9(4):195-201. X9. [pmid: 24391405].
114 Hickey CA, Cliver SP, Goldenberg RL, Blankson ML. Maternal weight status and term birth weight in first and second adolescent pregnancies. J Adolesc Health. 1992;13(7):561-9. X17. [pmid: 1420210].
115 Hickey CA, Cliver SP, Goldenberg RL, McNeal SF, Hoffman HJ. Relationship of psychosocial status to low prenatal weight gain among nonobese black and white women delivering at term. Obstet Gynecol. 1995;86(2):177-83. B, X8. [pmid: 7617346].
116 Hickey CA, Cliver SP, Goldenberg RL, McNeal SF, Hoffman HJ. Low prenatal weight gain among low-income women: what are the risk factors?. Birth. 1997;24(2):102-8. X9. [pmid: 9271976].
117 Hickey CA, Cliver SP, McNeal SF, Goldenberg RL. Low pregravid body mass index as a risk factor for preterm birth: variation by ethnic group. Obstet Gynecol. 1997;89(2):206-12. X14. [pmid: 9015021].
118 Hirose K, Tajima K, Hamajima N, Kuroishi T, Kuzuya K, Miura S, Tokudome S. Comparative case-referent study of risk factors among hormone-related female cancers in Japan. Jpn J Cancer Res. 1999;90(3):255-61. X1. [pmid: 10359038].
119 Homko CJ, Sivan E, Nyirjesy P, Reece EA. The interrelationship between ethnicity and gestational diabetes in fetal macrosomia. Diabetes Care. 1995;18(11):1442-5. X9. [pmid: 8722067].
120 Howie LD, Parker JD, Schoendorf KC. Excessive maternal weight gain patterns in adolescents. J Am Diet Assoc. 2003;103(12):1653-7. X14. [pmid: 14647096].
121 Hun DJ, Stoecker BJ, Hermann JR, Kopel BL, Williams GS, Claypool PL. Effects of nutrition education programs on anthropometric measurements and pregnancy outcomes of adolescents. J Am Diet Assoc. 2002;102(3 Suppl):S100-2. X4. [pmid: 11902382].
122 Hutcheon JA, Platt RW, Meltzer SJ, Egeland GM. Is birth weight modified during pregnancy? Using sibling differences to understand the impact of blood glucose, obesity, and maternal weight gain in gestational diabetes. Am J Obstet Gynecol. 2006;195(2):488-94. X9. [pmid: 16626616].
123 Ijuin H, Douchi T, Nakamura S, Oki T, Yamamoto S, Nagata Y. Possible association of body-fat distribution with preeclampsia. J Obstet Gynaecol Res. 1997;23(1):45-9. X1. [pmid: 9094817].
124 Jackson EA, Francke L, Vasilenko P. Management of gestational diabetes by family physicians and obstetricians. J Fam Pract. 1996;43(4):383-8. X1. [pmid: 8874374].
125 Jaksic J, Mikulandra F, Perisa M, Miletic T, Dubovecak Z, Skugor D, Tadin I. Effect of insulin and insulin-like growth factor I on fetal macrosomia in healthy women. Coll Antropol. 2001;25(2):535-43. X12. [pmid: 11811284].
126 Janney CA, Zhang D, Sowers M. Lactation and weight retention. Am J Clin Nutr. 1997;66(5):1116-1124. X14. [pmid: 9356528].
127 Jeffery AN, Voss LD, Metcalf BS, Wilkin TJ. The impact of pregnancy weight and glucose on the metabolic health of mother and child in the south west of the UK. Midwifery. 2004;20(3):281-9. X1. [pmid: 15337284].
128 Jensen DM, Damm P, Sorensen B, Molsted-Pedersen L, Westergaard JG, Ovesen P, Beck-Nielsen H. Pregnancy outcome and prepregnancy body mass index in 2459 glucose-tolerant Danish women. Am J Obstet Gynecol. 2003;189(1):239-44. X1. [pmid: 12861169].
129 Johnson PJ, Hellerstedt WL, Pirie PL. Abuse history and nonoptimal prenatal weight gain. Public Health Rep. 2002;117(2):148-56. X14. [pmid: 12356999].
130 Johnston CS, Christopher FS, Kandell LA. Pregnancy weight gain in adolescents and young adults. J Am Coll Nutr. 1991;10(3):185-9. X17. [pmid: 1894875].
131 Johnston CS, Kandell LA. Prepregnancy weight and rate of maternal weight gain in adolescents and young adults. J Am Diet Assoc. 1992;92(12):1515-7. X14. [pmid: 1452967].
132 Jonquil SG. Weight gain and pregnancy. Midwifery Today Childbirth Educ 1997(42):40–1. X2
133 Kahn HS, Tatham LM, Heath CW Jr. Contrasting factors associated with abdominal and peripheral weight gain among adult women. Int J Obes Relat Metab Disord. 1997;21(10):903-11. X1. [pmid: 9347409].
134 Kaijser M, Jacobsen G, Granath F, Cnattingius S, Ekbom A. Maternal age, anthropometrics and pregnancy oestriol. Paediatr Perinat Epidemiol. 2002;16(2):149-53. X1. [pmid: 12064269].
135 Kearney MH, Munro BH, Kelly U, Hawkins JW. Health behaviors as mediators for the effect of partner abuse on infant birth weight. Nurs Res. 2004;53(1):36-45. X1. [pmid: 14726775].
136 Kearney MH, Simonelli MC. Intervention fidelity: lessons learned from an unsuccessful pilot study. App Nurs Res. 2006;19(3):163-166. X4.
137 Kim I, Hungerford DW, Yip R, Kuester SA, Zyrkowski C, Trowbridge FL. Pregnancy nutrition surveillance system—United States, 1979-1990. MMWR CDC Surveill Summ. 1992;41(7):25-41. X2. [pmid: 1484524].
138 King JC. New National Academy of Sciences guidelines for nutrition during pregnancy. Diabetes. 1991;40(Suppl 2):151. X2. [pmid: 1748247].
139 Kinnunen TI, Luoto R, Gissler M, Hemminki E. Pregnancy weight gain from 1960s to 2000 in Finland. Int J Obes Relat Metab Disord. 2003;27(12):1572-7. X8. [pmid: 14517546].
140 Kinnunen TI, Pasanen M, Aittasalo M, Fogelholm M, Hilakivi-Clarke L, Weiderpass E, Luoto R. Preventing excessive weight gain during pregnancy - a controlled trial in primary health care. Eur J Clin Nutr. 2007;61(7):884-91. X14. [pmid: 17228348].
141 Kirchengast S, Gruber D, Sator M, Huber J. Postmenopausal weight status, body composition and body fat distribution in relation to parameters of menstrual and reproductive history. Maturitas. 1999;33(2):117-26. X17. [pmid: 10597875].
142 Konje JC, Palmer A, Watson A, Hay DM, Imrie A, Ewings P. Early teenage pregnancies in Hull. Br J Obstet Gynaecol. 1992;99(12):969-73. X14. [pmid: 1477018].
143 Kramer MS, Morin I, Yang H, Platt RW, Usher R, McNamara H, Joseph KS, Wen SW. Why are babies getting bigger? Temporal trends in fetal growth and its determinants. J Pediatr. 2002;141(4):538-42. B, X14. [pmid: 12378194].
144 Krueger PM, Scholl TO. Adequacy of prenatal care and pregnancy outcome. J Am Osteopath Assoc. 2000;100(8):485-92. X14. [pmid: 10979253].
145 Krummel DA. Postpartum weight control: a vicious cycle. J Am Diet Assoc. 2007;107(1):37-40. X2. [pmid: 17197268].
146 Lagiou P, Hsieh CC, Trichopoulos D, Xu B, Wuu J, Mucci L, Tamimi R, Adami HO, Cnattingius S. Birthweight differences between USA and China and their relevance to breast cancer aetiology. Int J Epidemiol. 2003;32(2):193-8. X12. [pmid: 12714535].
147 Lagiou P, Lagiou A, Samoli E, Hsieh CC, Adami HO, Trichopoulos D. Diet during pregnancy and levels of maternal pregnancy hormones in relation to the risk of breast cancer in the offspring. Eur J Cancer Prev. 2006;15(1):20-6. X1. [pmid: 16374225].
148 Lagiou P, Tamimi RM, Mucci LA, Adami HO, Hsieh CC, Trichopoulos D. Diet during pregnancy in relation to maternal weight gain and birth size. Eur J Clin Nutr. 2004;58(2):231-7. X1. [pmid: 14749741].
149 Lahmann PH, Lissner L, Gullberg B, Olsson H, Berglund G. A prospective study of adiposity and postmenopausal breast cancer risk: the Malmo Diet and Cancer Study. Int J Cancer. 2003;103(2):246-52. X1. [pmid: 12455040].
150 Landon MB, Thom E, Spong CY, Carpenter M, Mele L, Johnson F, Tillinghast J, Anderson G. The National Institute of Child Health and Human Development Maternal-Fetal Medicine Unit Network randomized clinical trial in progress: standard therapy versus no therapy for mild gestational diabetes. Diabet Care. 2007;30(Suppl 2):S194-9. X1.
151 Lao TT, Ho LF. Impact of iron deficiency anemia on prevalence of gestational diabetes mellitus. Diabetes Care. 2004;27(3):650-6. X1. [pmid: 14988280].
152 Lao TT, Wong KY. Perinatal outcome in large-for-gestational-age infants. Is it influenced by gestational impaired glucose tolerance?. J Reprod Med. 2002;47(6):497-502. X1. [pmid: 12092021].
153 Lauszus FF, Paludan J, Klebe JG. Birthweight in women with potential gestational diabetes mellitus—an effect of obesity rather than glucose intolerance?. Acta Obstet Gynecol Scand. 1999;78(6):520-5. X17. [pmid: 10376862].
154 Lawoyin TO. A prospective study on some factors which influence the delivery of large babies. J Trop Med Hyg. 1993;96(6):352-6. X12. [pmid: 8254713].
155 Lederman SA, Alfasi G, Deckelbaum RJ. Pregnancy-associated obesity in black women in New York City. Matern Child Health J. 2002;6(1):37-42. X14. [pmid: 11926252].
156 Lepercq J, Hauguel-De Mouzon S, Timsit J, Catalano PM. Fetal macrosomia and maternal weight gain during pregnancy. Diabet Metab. 2002;28(4 Pt 1):323-8. X14.
157 Levine RJ, Ewell MG, Hauth JC, Curet LB, Catalano PM, Morris CD, Choudhary G, Sibai BM. Should the definition of preeclampsia include a rise in diastolic blood pressure of >/=15 mm Hg to a level <90 mm Hg in association with proteinuria?. Am J Obstet Gynecol. 2000;183(4):787-92. X17. [pmid: 11035314].
158 Linne Y, Rossner S. Interrelationships between weight development and weight retention in subsequent pregnancies: the SPAWN study. Acta Obstet Gynecol Scand. 2003;82(4):318-25. X17. [pmid: 12716315].
159 Little RE. Weight gain and relation to maternal smoking. J Epidemiol Community Health. 1999;53(4):256. X2. [pmid: 10396556].
160 Lo T, Candido G, Janssen P. Diastasis of the Recti abdominis in pregnancy: risk factors and treatment. Physiotherapy Canada. 1999;51(1):32. X14.
161 Lucas A, Fewtrell MS, Davies PS, Bishop NJ, Clough H, Cole TJ. Breastfeeding and catch-up growth in infants born small for gestational age. Acta Paediatr. 1997;86(6):564-9. X1. [pmid: 9202788].
162 Luciano A, Bolognani M, Biondani P, Ghizzi C, Zoppi G, Signori E. The influence of maternal passive and light active smoking on intrauterine growth and body composition of the newborn. Eur J Clin Nutr. 1998;52(10):760-3. X8. [pmid: 9805225].
163 Luke B. Maternal weight, body mass index, and cesarean delivery. Am J Obstet Gynecol. 1998;179(2):564. X2. [pmid: 9731877].
164 Magann EF, Winchester MI, Carter DP, Martin JN Jr, Bass JD, Morrison JC. Factors adversely affecting pregnancy outcome in the military. Am J Perinatol. 1995;12(6):462-6. X8. [pmid: 8579664].
165 Maloni JA, Alexander GR, Schluchter MD, Shah DM, Park S. Antepartum bed rest: maternal weight change and infant birth weight. Biol Res Nurs. 2004;5(3):177-86. X9. [pmid: 14737918].
166 Marceau P, Kaufman D, Biron S, Hould FS, Lebel S, Marceau S, Kral JG. Outcome of pregnancies after biliopancreatic diversion. Obes Surg. 2004;14(3):318-24. X9. [pmid: 15072650].
167 Marsoosi V, Jamal A, Eslamian L. Pre-pregnancy weight, low pregnancy weight gain, and preterm delivery. Int J Gynaecol Obstet. 2004;87(1):36-7. X12. [pmid: 15464775].
168 Martinez H, Allen LH, Lung'aho M, Chavez A, Pelto GH. Maternal fatness in Mexican women predicts body composition changes in pregnancy and lactation. Adv Exp Med Biol. 1994;352:99-107. X12. [pmid: 7832062].
169 McAnarney ER, Stevens-Simon C. First, do no harm. Low birth weight and adolescent obesity. Am J Dis Child. 1993;147(9):983-5. X2. [pmid: 8362818].
170 McFarland MB, Trylovich CG, Langer O. Anthropometric differences in macrosomic infants of diabetic and nondiabetic mothers. J Matern Fetal Med. 1998;7(6):292-5. X14. [pmid: 9848695].
171 Meyers-Seifer CH, Vohr BR. Lipid levels in former gestational diabetic mothers. Diabetes Care. 1996;19(12):1351-6. X1. [pmid: 8941463].
172 Mikode MS, White AA. Dietary assessment of middle-income pregnant women during the first, second, and third trimesters. J Am Diet Assoc. 1994;94(2):196-9. X4. [pmid: 8300999].
173 Millard GL, Beerman KA, Massey L, Shulz T, Heiss C. Pregnancy and birth outcomes of high-risk women participating in a multidisciplinary intervention program. Topics Clin Nutr;14(4):64–75. X14
174 Miser WF. Outcome of infants born with nuchal cords. J Fam Pract. 1992;34(4):441-5. X1. [pmid: 1556538].
175 Misra DP, Kiely JL. The effect of smoking on the risk of gestational hypertension. Early Hum Dev. 1995;40(2):95-107. X1. [pmid: 7750444].
176 Mohamed N, Dooley J. Gestational diabetes and subsequent development of NIDDM in aboriginal women of northwestern Ontario. Int J Circumpolar Health. 1998;57(Suppl 1):355-8. X12. [pmid: 10093305].
177 Mongoven M, Dolan-Mullen P, Groff JY, Nicol L, Burau K. Weight gain associated with prenatal smoking cessation in white, non-Hispanic women. Am J Obstet Gynecol. 1996;174(1 Pt 1):72-7. X14. [pmid: 8572037].
178 Montgomery KS. Improving nutrition in pregnant adolescents: recommendations for clinical practitioners. J Perinat Educ. 2003;12(2):22-30. X2. [pmid: 17273337].
179 Moreira P, Padez C, Mourao-Carvalhal I, Rosado V. Maternal weight gain during pregnancy and overweight in Portuguese children. Int J Obes (Lond). 2007;31(4):608-14. X17. [pmid: 17384661].
180 Morin K, Gennaro S, Fehder W. Nutrition and exercise in overweight and obese postpartum women. App Nurs Res. 1999;12(1):13-21. X14.
181 Moses RG, Luebcke M, Davis WS, Coleman KJ, Tapsell LC, Petocz P, Brand-Miller JC. Effect of a low-glycemic-index diet during pregnancy on obstetric outcomes. Am J Clin Nutr. 2006;84(4):807-12. X14. [pmid: 17023707].
182 Mottola MF, Campbell MK. Activity patterns during pregnancy. Can J Appl Physiol. 2003;28(4):642-53. X14. [pmid: 12904639].
183 Nafstad P, Jaakkola JJ, Hagen JA, Pedersen BS, Qvigstad E, Botten G, Kongerud J. Weight gain during the first year of life in relation to maternal smoking and breast feeding in Norway. J Epidemiol Community Health. 1997;51(3):261-5. X1. [pmid: 9229054].
184 Napoli A, Sabbatini A, Di Biase N, Marceca M, Colatrella A, Fallucca F. Twenty-four-hour blood pressure monitoring in normoalbuminuric normotensive type 1 diabetic women during pregnancy. J Diabet Complic. 2003;17(5):292-6. X1.
185 Neggers YH, Goldenberg RL, Ramey SL, Cliver SP. Maternal prepregnancy body mass index and psychomotor development in children. Acta Obstet Gynecol Scand. 2003;82(3):235-40. X17. [pmid: 12694119].
186 Neher JO. Transforming practice. New evidence challenges IOM gestational weight gain goals. Evidence-Based Practice. 2007;10(8):1-3. 2p. X2.
187 Ng SC, Gomez JM, Rajadurai VS, Saw SM, Quak SH. Establishing enteral feeding in preterm infants with feeding intolerance: a randomized controlled study of low-dose erythromycin. J Pediatr Gastroenterol Nutr. 2003;37(5):554-8. X1. [pmid: 14581796].
188 Nielsen GL, Dethlefsen C, Moller M, Sorensen HT. Maternal glycated haemoglobin, pre-gestational weight, pregnancy weight gain and risk of large-for-gestational-age babies: a Danish cohort study of 209 singleton Type 1 diabetic pregnancies. Diabet Med. 2007;24(4):384-7. X9. [pmid: 17335464].
189 Nohira T, Kim S, Nakai H, Okabe K, Nohira T, Yoneyama K. Recurrence of gestational diabetes mellitus: rates and risk factors from initial GDM and one abnormal GTT value. Diabetes Res Clin Pract. 2006;71(1):75-81. X1. [pmid: 16005100].
190 Ohlin A, Rossner S. Trends in eating patterns, physical activity and socio-demographic factors in relation to postpartum body weight development. Br J Nutr. 1994;71(4):457-70. X14. [pmid: 8011603].
191 Ohlin A, Rossner S. Factors related to body weight changes during and after pregnancy: the Stockholm Pregnancy and Weight Development Study. Obes Res. 1996;4(3):271-6. X17. [pmid: 8732961].
192 Olausson PM, Cnattingius S, Goldenberg RL. Determinants of poor pregnancy outcomes among teenagers in Sweden. Obstet Gynecol. 1997;89(3):451-7. X17. [pmid: 9052604].
193 Olsen J. Cigarette smoking in pregnancy and fetal growth. Does the type of tobacco play a role?. Int J Epidemiol. 1992;21(2):279-84. X17. [pmid: 1428481].
194 Olson CM, Strawderman MS. Modifiable behavioral factors in a biopsychosocial model predict inadequate and excessive gestational weight gain. J Am Diet Assoc. 2003;103(1):48-54. B, X8. [pmid: 12525793].
195 Olson CM, Strawderman MS, Reed RG. Efficacy of an intervention to prevent excessive gestational weight gain. Am J Obstet Gynecol. 2004;191(2):530-6. X14. [pmid: 15343232].
196 O'Neill ME, Cooper KA, Hunyor SN, Boyce GS. Maternal heart rate response to low-intensity weight-bearing exercise. J Appl Physiol. 1991;70(3):1407-9. X1. [pmid: 2033011].
197 Ouzilleau C, Roy MA, Leblanc L, Carpentier A, Maheux P. An observational study comparing 2-hour 75-g oral glucose tolerance with fasting plasma glucose in pregnant women: both poorly predictive of birth weight. Can Med Assoc J. 2003;168(4):403-9. X17. [pmid: 12591779].
198 Parker JD, Abrams B. Differences in postpartum weight retention between black and white mothers. Obstet Gynecol. 1993;81(5 Pt 1):768-74. X17. [pmid: 8469470].
199 Patterson RJ, Ellerbee S, Powell MJ, Thompson PJ, Jackson E. Evaluation of a clinic for pregnant adolescents. J Ark Med Soc. 1994;91(3):131-4. X14. [pmid: 9132405].
200 Perez R, Patience T, Pulous E, Brown G, McEwen A, Asato A, Hume R, Calhoun BC. Use of a focussed teen prenatal clinic at a military teaching hospital: model for improved outcomes of unmarried mothers. Aust N Z J Obstet Gynaecol. 1998;38(3):280-3. X1. [pmid: 9761153].
201 Perry RL, Mannino B, Hediger ML, Scholl TO. Pregnancy in early adolescence: are there obstetric risks?. J Matern Fetal Med. 1996;5(6):333-9. X1. [pmid: 8972410].
202 Peters RK, Kjos SL, Xiang A, Buchanan TA. Long-term diabetogenic effect of single pregnancy in women with previous gestational diabetes mellitus. Lancet. 1996;347(8996):227-30. X1. [pmid: 8551882].
203 Piers LS, Diggavi SN, Thangam S, van Raaij JMA, Shetty PS, Hautvast JGA. Changes in energy expenditure, anthropometry, and energy intake during the course of pregnancy and lactation in well-nourished Indian women. Am J Clin Nutr. 1995;61(3):501-513. X12. [pmid: 7872213].
204 Pole JD, Dodds LA. Maternal outcomes associated with weight change between pregnancies. Can J Public Health. 1999;90(4):233-6. X1. [pmid: 10489718].
205 Polley BA, Wing RR, Sims CJ. Randomized controlled trial to prevent excessive weight gain in pregnant women. Int J Obes Relat Metab Disord. 2002;26(11):1494-502. X14. [pmid: 12439652].
206 Poppitt SD, Prentice AM, Goldberg GR, Whitehead RG. Energy-sparing strategies to protect human fetal growth. Am J Obstet Gynecol. 1994;171(1):118-25. X8. [pmid: 8030686].
207 Poppitt SD, Prentice AM, Jequier E, Schutz Y, Whitehead RG. Evidence of energy sparing in Gambian women during pregnancy: a longitudinal study using whole-body calorimetry. Am J Clin Nutr. 1993;57(3):353-64. X12. [pmid: 8438769].
208 Prozialeck LL, Pesole L. Performing a program evaluation in a family case management program: determining outcomes for low birthweight deliveries. Public Health Nurs. 2000;17(3):195-201. X4. [pmid: 10840289].
209 Prysak M, Lorenz RP, Kisly A. Pregnancy outcome in nulliparous women 35 years and older. Obstet Gynecol. 1995;85(1):65-70. X14. [pmid: 7800328].
210 Qureshi IA, Xi XR, Limbu YR, Bin HY, Chen MI. Hyperlipidaemia during normal pregnancy, parturition and lactation. Ann Acad Med Singapore. 1999;28(2):217-21. X12. [pmid: 10497670].
211 Rasmussen KM, Adams B. Annotation: cigarette smoking, nutrition, and birthweight... The effects of cigarette smoking and gestational weight change on birth outcomes in obese and normal-weight women. Am J Public Health 1997;87:591–596. Am J Pub Health. 1997;87(4):543-544. X2. [pmid: 9146425].
212 Ratner RE, Hamner LH 3rd, Isada NB. Effects of gestational weight gain in morbidly obese women: II: Fetal morbidity. Am J Perinatol. 1990;7(4):295-9. X10. [pmid: 2222615].
213 Ray JG, Vermeulen MJ, Shapiro JL, Kenshole AB. Maternal and neonatal outcomes in pregestational and gestational diabetes mellitus, and the influence of maternal obesity and weight gain: the DEPOSIT study. Diabetes Endocrine Pregnancy Outcome Study in Toronto. Q J Med. 2001;94(7):347-56. X9.
214 Reece EA, Lequizamon G, Silva J, Whiteman V, Smith D. Intensive interventional maternity care reduces infant morbidity and hospital costs. J Matern Fetal Neonatal Med. 2002;11(3):204-10. X14. [pmid: 12380679].
215 Retnakaran R, Hanley AJ, Raif N, Connelly PW, Sermer M, Zinman B. Hypoadiponectinaemia in South Asian women during pregnancy: evidence of ethnic variation in adiponectin concentration. Diabet Med. 2004;21(4):388-92. X1. [pmid: 15049945].
216 Rhodes JC, Schoendorf KC, Parker JD. Contribution of excess weight gain during pregnancy and macrosomia to the cesarean delivery rate, 1990-2000. Pediatrics. 2003;111(5):1181-1185. X17. [pmid: 12728135].
217 Richardson P. Women's experiences of body change during normal pregnancy. Maternal-Child Nurs J. 1990;19(2):93-111. X14.
218 Roberts LA. Cesarean section. Am J Obstet Gynecol. 1998;179(2):564-5. X2. [pmid: 9731878].
219 Rooks JP, Weatherby NL, Ernst EKM. The National Birth Center Study — methodology and prenatal care and referrals... part 1. J Nurse-Midwifery. 1992;37(4):222-253. X14. [pmid: 1403170].
220 Rosenberg L, Palmer JR, Wise LA, Horton NJ, Kumanyika SK, Adams-Campbell LL. A prospective study of the effect of childbearing on weight gain in African-American women. Obes Res. 2003;11(12):1526-35. X17. [pmid: 14694218].
221 Rossner S. Pregnancy, weight cycling and weight gain in obesity. Int J Obes Relat Metab Disord. 1992;16(2):145-7. X8. [pmid: 1316328].
222 Rota S, Yildirim B, Kaleli B, Aybek H, Duman K, Kaptanoglu B. C-reactive protein levels in non-obese pregnant women with gestational diabetes. Tohoku J Exp Med. 2005;206(4):341-5. X12. [pmid: 15997206].
223 Rudolph CM, Al-Fares S, Vaughan-Jones SA, Mullegger RR, Kerl H, Black MM. Polymorphic eruption of pregnancy: clinicopathology and potential trigger factors in 181 patients. Br J Dermatol. 2006;154(1):54-60. X9. [pmid: 16403094].
224 Rydhstrom H, Tyden T, Herbst A, Ljungblad U, Walles B. No relation between maternal weight gain and stillbirth. Acta Obstet Gynecol Scand. 1994;73(10):779-81. X17. [pmid: 7817728].
225 Salsberry PJ, Reagan PB. Taking the long view: the prenatal environment and early adolescent overweight. Res Nurs Health. 2007;30(3):297-307. X1. [pmid: 17514704].
226 Sanderson M, Gonzalez JF. 1988 National Maternal and Infant Health Survey: methods and response characteristics. Vital Health Stat 2 1998(125):1–39. X1
227 Sanin Aguirre LH, Reza-Lopez S, Levario-Carrillo M. Relation between maternal body composition and birth weight. Biol Neonate. 2004;86(1):55-62. X12. [pmid: 15057023].
228 Savitz DA, Whelan EA, Rowland AS, Kleckner RC. Maternal employment and reproductive risk factors. Am J Epidemiol. 1990;132(5):933-45. X17. [pmid: 2239908].
229 Schauberger CW, Rooney BL, Brimer LM. Factors that influence weight loss in the puerperium. Obstet Gynecol. 1992;79(3):424-9. X17. [pmid: 1738527].
230 Schieve LA, Perry GS, Cogswell ME, Scanion KS, Rosenberg D, Carmichael S, Ferre C. Validity of self-reported pregnancy delivery weight: an analysis of the 1988 National Maternal and Infant Health Survey. NMIHS Collaborative Working Group. Am J Epidemiol. 1999;150(9):947-56. X1. [pmid: 10547140].
231 Schmitt K. Chlamydial infection in pregnancy: An association with low birth weight [Ph.D.]: University of Florida; 1999.
232 Scholl TO, Chen X. Insulin and the “thrifty” woman: the influence of insulin during pregnancy on gestational weight gain and postpartum weight retention. Matern Child Health J. 2002;6(4):255-61. X8. [pmid: 12512767].
233 Scholl TO, Hediger ML. Weight gain, nutrition, and pregnancy outcome: findings from the Camden study of teenage and minority gravidas. Semin Perinatol. 1995;19(3):171-81. X2. [pmid: 7570069].
234 Scholl TO, Hediger ML, Fischer RL, Shearer JW. Anemia vs iron deficiency: increased risk of preterm delivery in a prospective study. Am J Clin Nutr. 1992;55(5):985-8. X14. [pmid: 1570808].
235 Scholl TO, Hediger ML, Vasilenko P, III, Healy MF. Growth and nutrition during adolescent pregnancy Growth and nutrition during adolescent pregnancy. In: Malnourished children in the United States: caught in the cycle of poverty. New York: Springer Publishing; 1993. p. 156–167.
236 Sebire NJ, Jolly M, Harris JP, Wadsworth J, Joffe M, Beard RW, Regan L, Robinson S. Maternal obesity and pregnancy outcome: a study of 287,213 pregnancies in London. Int J Obes Relat Metab Disord. 2001;25(8):1175-82. X1. [pmid: 11477502].
237 Segal MR, Wight S, Hanrahan JP, Tager IB. Maternal smoking during pregnancy and birth outcomes with weight gain adjustments via varying-coefficient models. Stat Med. 1997;16(14):1603-16. X1. [pmid: 9257415].
238 Selvin S, Abrams B. Analysing the relationship between maternal weight gain and birthweight: exploration of four statistical issues. Paediatr Perinat Epidemiol. 1996;10(2):220-34. X14. [pmid: 8778694].
239 Shaarawy M, el-Mallah SY. Leptin and gestational weight gain: relation of maternal and cord blood leptin to birth weight. J Soc Gynecol Investig. 1999;6(2):70-3. X12.
240 Sharma R, Synkewecz C, Raggio T, Mattison DR. Intermediate variables as determinants of adverse pregnancy outcome in high-risk inner-city populations. J Natl Med Assoc. 1994;86(11):857-60. X17. [pmid: 7807574].
241 Shrewsbury VA, Garnett SP, Cowell CT, Crawford D, Baur LA. Change in women's body mass index and waist circumference, 1997 to 2002: the Nepean Study. Aust N Z J Public Health. 2005;29(2):183-6. X14. [pmid: 15915625].
242 Siega-Riz AM, Hobel CJ. Predictors of poor maternal weight gain from baseline anthropometric, psychosocial, and demographic information in a Hispanic population. J Am Diet Assoc. 1997;97(11):1264-8. X14, B. [pmid: 9366864].
243 Skull AJ, Slater GH, Duncombe JE, Fielding GA. Laparoscopic adjustable banding in pregnancy: safety, patient tolerance and effect on obesity-related pregnancy outcomes. Obes Surg. 2004;14(2):230-5. X9. [pmid: 15018752].
244 Smith DE, Lewis CE, Caveny JL, Perkins LL, Burke GL, Bild DE. Longitudinal changes in adiposity associated with pregnancy. The CARDIA Study. Coronary Artery Risk Development in Young Adults Study. J Am Med Assoc. 1994;271(22):1747-51. X14.
245 Sohlstrom A, Forsum E. Changes in adipose tissue volume and distribution during reproduction in Swedish women as assessed by magnetic resonance imaging. Am J Clin Nutr. 1995;61(2):287-295. X4. [pmid: 7840065].
246 Solomon CG, Willett WC, Carey VJ, Rich-Edwards J, Hunter DJ, Colditz GA, Stampfer MJ, Speizer FE, Spiegelman D, Manson JE. A prospective study of pregravid determinants of gestational diabetes mellitus. J Am Med Assoc. 1997;278(13):1078-83. X1.
247 Sowers M, Zhang D, Janney CA. Interpregnancy weight retention patterning in women who breastfed. J Matern Fetal Med. 1998;7(2):89-94. X14. [pmid: 9584821].
248 Stage E, Ronneby H, Damm P. Lifestyle change after gestational diabetes. Diabetes Res Clin Pract. 2004;63(1):67-72. X1. [pmid: 14693414].
249 Steegers EA, Van Lakwijk HP, Jongsma HW, Fast JH, De Boo T, Eskes TK, Hein PR. (Patho)physiological implications of chronic dietary sodium restriction during pregnancy; a longitudinal prospective randomized study. Br J Obstet Gynaecol. 1991;98(10):980-7. X4. [pmid: 1751444].
250 Stein AD, Ravelli AC, Lumey LH. Famine, third-trimester pregnancy weight gain, and intrauterine growth: the Dutch Famine Birth Cohort Study. Hum Biol. 1995;67(1):135-50. X17. [pmid: 7721275].
251 Stein TP, Scholl TO, Schluter MD, Schroeder CM. Plasma leptin influences gestational weight gain and postpartum weight retention. Am J Clin Nutr. 1998;68(6):1236-40. X14. [pmid: 9846852].
252 Stephansson O, Dickman PW, Johansson A, Cnattingius S. Maternal weight, pregnancy weight gain, and the risk of antepartum stillbirth. Am J Obstet Gynecol. 2001;184(3):463-9. X17. [pmid: 11228504].
253 Sternfeld B, Quesenberry CP Jr, Eskenazi B, Newman LA. Exercise during pregnancy and pregnancy outcome. Med Sci Sports Exerc. 1995;27(5):634-40. X8. [pmid: 7674866].
254 Stevens-Simon C, Fullar S, McAnarney ER. Tangible differences between adolescent-oriented and adult-oriented prenatal care. J Adolesc Health Care. 1992;13(4):298-302. X14.
255 Stevens-Simon C, McAnarney ER. Skeletal maturity and growth of adolescent mothers: relationship to pregnancy outcome. J Adolesc Health. 1993;14(6):428-32. X14. [pmid: 8241197].
256 Stevens-Simon C, McAnarney ER. Childhood victimization: relationship to adolescent pregnancy outcome. Child Abuse Negl. 1994;18(7):569-75. X1. [pmid: 7922731].
257 Stevens-Simon C, Roghmann KJ, McAnarney ER. Relationship of self-reported prepregnant weight and weight gain during pregnancy to maternal body habitus and age. J Am Diet Assoc. 1992;92(1):85-7. X5. [pmid: 1728630].
258 Stevens-Simon C, Thureen P, Barrett J, Stamm E. Regional body fat distribution and insulin resistance during adolescent pregnancy. J Am Diet Assoc. 2002;102(4):563-5. X4. [pmid: 11985419].
259 Stevens-Simon C, Thureen P, Barrett J, Stamm E. Research and professional briefs. Regional body fat distribution and insulin resistance during adolescent pregnancy. J Am Diet Assoc. 2002;102(4):563-565. X4. [pmid: 11985419].
260 Stone SE. Factors associated with a high rate of cesarean section in a small rural hospital [D.N.Sc.]: University of Tennessee Center for the Health Sciences; 2001.
261 Stotland NE, Haas JS, Brawarsky P, Jackson RA, Fuentes-Afflick E, Escobar GJ. Body mass index, provider advice, and target gestational weight gain. Obstet Gynecol. 2005;105(3):633-8. X14, B. [pmid: 15738036].
262 Strychar IM, Chabot C, Champagne F, Ghadirian P, Leduc L, Lemonnier MC, Raynauld P. Psychosocial and lifestyle factors associated with insufficient and excessive maternal weight gain during pregnancy. J Am Diet Assoc. 2000;100(3):353-6. X14. [pmid: 10719411].
263 Sutton L, Sayer GP, Bajuk B, Richardson V, Berry G, Henderson-Smart DJ. Do very sick neonates born at term have antenatal risks? 2. Infants ventilated primarily for lung disease. Acta Obstet Gynecol Scand. 2001;80(10):917-25. X1. [pmid: 11580736].
264 Taffel SM. Cesarean delivery in the United States, 1990. Vital Health Stat 21 1994(51):1–24. X8
265 Taffel SM, Keppel KG, Jones GK. Medical advice on maternal weight gain and actual weight gain. Results from the 1988 National Maternal and Infant Health Survey. Ann N Y Acad Sci. 1993;678:293-305. B, X8. [pmid: 8494272].
266 Tavares M, Rodrigues T, Cardoso F, Barros H, Leite LP. Independent effect of maternal birth weight on infant birth weight. J Perinat Med. 1996;24(4):391-6. X17. [pmid: 8880637].
267 Theron GB, Thompson ML. The usefulness of weight gain in predicting pregnancy complications. J Trop Pediatr. 1993;39(5):269-72. X12. [pmid: 8271332].
268 Trujillo K, Harvey-Banchik L. Hyperemesis gravidarum: feed the mother, feed the child. J Parenter Enteral Nutr. 2005;29(2):134-5. X2.
269 Turhan NO, Seckin NC, Aybar F, Inegol I. Assessment of glucose tolerance and pregnancy outcome of polycystic ovary patients. Int J Gynaecol Obstet. 2003;81(2):163-8. X9. [pmid: 12706273].
270 Turner RE, Langkamp-Henken B, Littell R. Update on adequacy of protein and energy intake during pregnancy. J Am Diet Assoc. 2003;103(5):563. X2. [pmid: 12728211].
271 Turner RE, Langkamp-Henken B, Littell RC, Lukowski MJ, Suarez MF. Comparing nutrient intake from food to the estimated average requirements shows middle- to upper-income pregnant women lack iron and possibly magnesium. J Am Diet Assoc. 2003;103(4):461-466. X14. [pmid: 12669009].
272 Vahratian A, Siega-Riz AM, Savitz DA, Zhang J. Maternal pre-pregnancy overweight and obesity and the risk of cesarean delivery in nulliparous women. Ann Epidemiol. 2005;15(7):467-474. X1. [pmid: 15921926].
273 Vallianatos H, Brennand EA, Raine K, Stephen Q, Petawabano B, Dannenbaum D, Willows ND. Beliefs and practices of First Nation women about weight gain during pregnancy and lactation: implications for women's health. Can J Nurs Res. 2006;38(1):102-19. X5. [pmid: 16671283].
274 van Bogaert LJ. Maternal end-pregnancy ponderal index and birth weight. J Obstet Gynaecol. 2005;25(4):353-4. X12. [pmid: 16091316].
275 van der Maten GD. Low sodium diet in pregnancy: effects on maternal nutritional status. Eur J Obstet Gynecol Reprod Biol. 1995;61(1):63-4. X14. [pmid: 8549849].
276 van der Maten GD, van Raaij JM, Visman L, van der Heijden LJ, Oosterbaan HP, de Boer R, Eskes TK, Hautvast JG. Low-sodium diet in pregnancy: effects on blood pressure and maternal nutritional status. Br J Nutr. 1997;77(5):703-20. X1. [pmid: 9175991].
277 Van Wootten W, Turner RE. Macrosomia in neonates of mothers with gestational diabetes is associated with body mass index and previous gestational diabetes. J Am Diet Assoc. 2002;102(2):241-3. X17. [pmid: 11846118].
278 Ventura SJ, Martin JA, Curtin SC, Mathews TJ. Births: final data for 1997. Natl Vital Stat Rep. 1999;47(18):1-96. X8.
279 Vik T, Jacobsen G, Vatten L, Bakketeig LS. Pre- and post-natal growth in children of women who smoked in pregnancy. Early Hum Dev. 1996;45(3):245-55. X1. [pmid: 8855398].
280 Villamor E, Cnattingius S. Interpregnancy weight change and risk of adverse pregnancy outcomes: a population-based study. Lancet. 2006;368(9542):1164-70. X1. [pmid: 17011943].
281 Walker LO. Weight-related distress in the early months after childbirth. West J Nurs Res. 1998;20(1):30-44. X17. [pmid: 9473966].
282 Walker LO, Freeland-Graves JH, Milani T, Hanss-Nuss H, George G, Sterling BS, Kim M, Timmerman GM, Wilkinson S, Arheart KL, Stuifbergen A. Weight and behavioral and psychosocial factors among ethnically diverse, low-income women after childbirth: I. Methods and context. Women Health. 2004;40(2):1-17. X1. [pmid: 15778135].
283 Walker LO, Kim M. Psychosocial thriving during late pregnancy: relationship to ethnicity, gestational weight gain, and birth weight. J Obstet Gynecol Neonatal Nurs. 2002;31(3):263-74. X8 (wrong outcome).
284 Walker LO, Timmerman GM, Sterling BS, Kim M, Dickson P. Keeping pregnancy-related weight may result in long-term weight problems for women. Ethn Dis. 2004;14(1):161-2. X2. [pmid: 15002941].
285 Wen SW, Kramer MS. Etiologic fraction analysis for continuously distributed outcome variables and empirical analogy with dichotomized outcome variables. Int J Epidemiol. 1995;24(2):457-61. X1. [pmid: 7635611].
286 Wiles R. The views of women of above average weight about appropriate weight gain in pregnancy. Midwifery. 1998;14(4):254-260. X4. [pmid: 10076321].
287 Williamson DF, Madans J, Pamuk E, Flegal KM, Kendrick JS, Serdula MK. A prospective study of childbearing and 10-year weight gain in US white women 25 to 45 years of age. Int J Obes Relat Metab Disord. 1994;18(8):561-9. X1. [pmid: 7951478].
288 Witter FR. Epidemiology, antenatal screening, nutrition, and therapeutics in pregnancy. Curr Opin Obstet Gynecol. 1990;2(1):36-9. X2. [pmid: 2102302].
289 Wolfe HM, Gross TL. Obesity in pregnancy. Clin Obstet Gynecol. 1994;37(3):596-604. X8. [pmid: 7955647].
290 Wolfe WS, Sobal J, Olson CM, Frongillo EA Jr. Parity-associated body weight: modification by sociodemographic and behavioral factors. Obes Res. 1997;5(2):131-41. X14. [pmid: 9112248].
291 Wolfe WS, Sobal J, Olson CM, Frongillo EA Jr, Williamson DF. Parity-associated weight gain and its modification by sociodemographic and behavioral factors: a prospective analysis in US women. Int J Obes Relat Metab Disord. 1997;21(9):802-10. X1. [pmid: 9376894].
292 Wong W, Tang NLS, Lau TK, Wong TW. Research. A new recommendation for maternal weight gain in Chinese women. J Am Diet Assoc. 2000;100(7):791-796. X12. [pmid: 10916517].
293 Woolbright LA. Postneonatal mortality in Alabama: why no progress in the 90s?. Ann Epidemiol. 2001;11(3):208-212. X17. [pmid: 11248585].
294 Xiao R, Sorensen TK, Williams MA, Luthy DA. Influence of pre-eclampsia on fetal growth. J Matern Fetal Neonatal Med. 2003;13(3):157-62. X1. [pmid: 12820837].
295 Xu B, Jarvelin MR, Pekkanen J. Prenatal factors and occurrence of rhinitis and eczema among offspring. Allergy. 1999;54(8):829-36. X1. [pmid: 10485386].
296 Yamamoto S, Douchi T, Yoshimitsu N, Nakae M, Nagata Y. Waist to hip circumference ratio as a significant predictor of preeclampsia, irrespective of overall adiposity. J Obstet Gynaecol Res. 2001;27(1):27-31. X14. [pmid: 11330727].
297 Yanagisawa K, Iwasaki N, Sanaka M, Minei S, Kanamori M, Omori Y, Iwamoto Y. Polymorphism of the beta3-adrenergic receptor gene and weight gain in pregnant diabetic women. Diabetes Res Clin Pract. 1999;44(1):41-7. X9. [pmid: 10414939].
298 Yekta Z, Porali R, Aiatollahi H. The effect of pre-pregnancy body mass index, gestational weight gain on pregnancy outcomes. Internet J Health. 2005;4(2):9p. X12.
299 Yogev Y, Langer O. Recurrence of gestational diabetes: pregnancy outcome and birth weight diversity. J Matern Fetal Neonatal Med. 2004;15(1):56-60. X9. [pmid: 15101613].
300 Zeanah M, Schlosser SP. Adherence to ACOG guidelines on exercise during pregnancy: effect on pregnancy outcome. J Obstet Gynecol Neonatal Nurs. 1993;22(4):329-35. X1.
301 Zimmer-Gembeck MJ, Helfand M. Low birthweight in a public prenatal care program: behavioral and psychosocial risk factors and psychosocial intervention. Soc Sci Med. 1996;43(2):187-97. X17. [pmid: 8844923].